# Appendix B

## Screening/Data Abstraction Form

Study | Design and Quality | Patient Population | Study Protocol | Results | Notes
Study | Design: | N= | Interventions: | FEV_1_: | [Signif baseline diffs btwn tx grps; methodological probs; predictors of response (major outcomes only)]
| Dates: | Setting: | Experimental: | FVC: [If only and if no FEV_1_]
| Location: | Inclusion (COPD): | Control: | PEFR: [If and only if no FEV1 and no FVC]
| Assessment period: | Inclusion (AcEx): | Co-interventions: | Blood gases/oximetry: [NPPV and bronchodilator trials only]
| Quality: | Exclusion: | Outcomes: | Subjective symptom scores: [Mucolytic trials only]
| | Smoking history: | | Percentage of pts admitted to hospital: [If outpt or ED study]
| | Baseline stable FEV_1_: | | Length of stay in ED or hospital:
| | FEV_1_ at admission: | | Percentage of pts intubated: [NPPV trials only]
| | Age: | | Mortality: [Note: For NPPV trials, use the last period, up to and including 30 days, for which complete/reliable data are available]
| | Sex: | | Adverse events: [If no data reported, say so]
| | Race: | | Dropouts:

## Example of a completed screening/data abstraction form

Study | Design and Quality | Patient Population | Study Protocol | Results | Notes
Bullard, Liaw, Tsai, et al, 1996 | Design: SPPG | N= 138 | Interventions: | FEV_1_: (a) Mean improvement from 0–6 hrs was statistically significant in the steroid group (n = 60) (p < 0.05), but not in the placebo group (n = 53) (p > 0.05). The two groups were not directly compared. | Patients with asthma were explicitly not excluded
| Dates: Mar-Aug 1993, Nov1993-Feb 1994 | Setting: ED | Experimental: Hydrocortisone IV 100 mg, administered w/in 15 min of admission to ED | Steroids: 0.14 (95% Cl, 0.07–0.22) | Initial serum theophyl-line levels significantly higher in the placebo group (10.4 μg/dL vs. 6.39 μg/dL)
| Location: Taiwan | Inclusion (COPD): Age> 40 yrs; evidence of chronic airflow obstruction (no further details provided) | Control: Placebo | Placebo: 0.02 (0.08–0.12) | Both groups averaged 2 fenoterol nebulizations over first 6 hrs
| Assessment period: 6 hrs | Inclusion (AcEx): Dyspnea plus FEV1 < 60% of predicted value and FEV1/FVC ratio <60% | Co-interventions: Aminophylline IV; nebulized fenoterol and ipratropium initially; nebulized feneterol repeated hourly, as required; oxygen | (b) No significant difference between the two groups in the number of patients with > 40% improvement in FEV_1_ from 0–6hrs (p > 0.05) | Data collected after admission to hospital not usable due to violations of treatment protocol
| Quality: 4 r, db+ (“identically marked,” “blinded to all study participants”), dd | Exclusion: Associated pneumothorax; radiological or clinical evidence of pneumonia; intubation w/in first 2 hrs; need to be hospitalized for another condition; known or suspected current use of steroids | Outcomes: | Steroids: 17/60 (28%)
| | Smoking history: N/S | FEV_1_: (a) Mean improvement from baseline (admission) to 15 min, 1 hr, and 6 hrs | Placebo: 8/53 (15%)
| | Baseline stable FEV_1_: N/S | (b) Number of patients with > 40% improvement in FEV_1_ from 0–6 hrs | Percentage of pts admitted to hospital: 44/60 receiving steroids (73%) and 42/53 (79%) receiving (not analyzed)
| | FEV_1_ at admission: Steroid group: 0.52±0.05 (SEM) = 26% pf predicted value; placebo group: 0.55±0.06 = 27% of predicted value | Percentage of patients admitted to hospital after 6 hrs | Adverse events: No data reported
| | Age: 65.99 | | Dropouts: 25 (18%) pts, treatment groups N/S; 4 of these 25 pts refused to continue after initial assessment for unspecified reasons; the remaining 21 were excluded, post-randomization, on the basis of the inclusion/exclusion criteria
| | Sex: 97 M. 16 F
| | Race: N/S