# Appendix A. Final Literature Search Strategies

The search strategies combined a concept for “COPD” with a “methods” concept and an “intervention” concept. A subset of the MEDLINE search with high specificity (high yield) was achieved by adding an “acute exacerbation” concept; this strategy was used in CCTR and EMBASE. We took special care to eliminate articles with asthma as the focus and articles with antibiotics as the focus.

The search terms and logic are presented below. These are the final search strategies; however, these were not the only searches that contributed citations to the literature review. Bibliographic database searches from the preliminary literature review during the topic assessment and refinement phase also contributed citations to the database.

Diagnosis/Prognosis topic - Run in Ovid-MEDLINE <1966-February 1999> database on 2/19/99; updated weekly (Ovid for UNIX, Version 3.0, Release 7.8 Millennium, Ovid Technologies, Inc.)

1. exp *lung diseases, obstructive/ or “lung diseases, obstructive”.mp.
2. (COPD or (chronic adj obstructive adj pulmonary adj disease) or (chronic adj bronchitis)).mp. [mp=title, abstract, registry number word, mesh subject heading]
3. 1 or 2
4. exp *asthma/ or “asthma”.mp.
5. 3 not 4
6. ((acute or exacerbation$ or flare$) adj6 ((chronic adj4 (bronchiti$ or pulmonary or lung)) or copd or cold)).mp.
7. 5 and 6
8. prognos$.ti,ab,sh.
9. predict$.ti,ab,sh.
10. course.ti,ab,sh.
11. exp mortality/
12. Follow-Up Studies/
13. mo.fs.
14. Survival Analysis/
15. prognosis.ti,ab,sh.
16. or/8–15
17. limit 16 to (human and english language and (adult < 19 to 44 years > or middle age < 45 to 64 years > or “aged < 65 and over >” or “aged, 80 and over”))
18. “Sensitivity and specificity”/
19. sensitivity.ti,ab,sh.
20. di.fs.
21. ri.fs.
22. du.fs.
23. specificity.ti,ab,sh.
24. exp sensitivity-and-specificity/
25. (predictive and value$).tw.
26. or/18–25
27. limit 26 to (human and english language and (adult < 19 to 44 years > or middle age < 45 to 64 years > or “aged < 65 and over >” or “aged, 80 and over”))
28. 7 and 17
29. 7 and 27
30. 28 or 29

Treatment topic - run in Ovid-MEDLINE <1966-February 1999> database on 2/23/99; updated weekly (Ovid for UNIX, Version 3.0, Release 7.8 Millennium, Ovid Technologies, Inc.)

1. exp *lung diseases, obstructive/ or “lung diseases, obstructive”.mp.
2. (copd or (chronic adj obstructive adj pulmonary adj disease) or (chronic adj bronchitis)).mp. [mp=title, abstract, registry number word, mesh subject heading]
3. 1 or 2
4. exp *Asthma/
5. 3 not 4
6. random$.ti,ab,sh.
7. tu.fs.
8. dt.fs.
9. randomized controlled trial.pt.
10. 6 or 7 or 8 or 9
11. (double and blind$).ti,ab,sh.
12. placebo$.ti,ab,sh.
13. 11 or 12
14. 10 or 13
15. 5 and 14
16. exp *Antibiotics/
17. 15 not 16
18. exp *bronchodilator agents/ or “##‘Bronchodilator$’.mp.##”/ or “bronchodilator$”.mp.
19. albuterol.tw. or aminophylline.tw. or atropine.tw. or clenbuterol.tw. or dyphylline.tw.
20. ephedrine.tw. or epinephrine.tw. or fenoterol.tw. or ipratropium.tw. or isoetharine.tw.
21. isoproterenol.tw. or pirbuterol.tw. or procaterol.tw. or terbutaline.tw. or theobromine.tw.
22. theophylline.tw. or tretoquinol.tw.
23. or/18–22
24. exp *adrenal cortex hormones/ or “corticosteroids”.mp.
25. beclomethasone.tw. or budesonide.tw. or dexamethasone.tw. or fluticasone.tw.
26. hydrocortisone.tw. or methylprednisolone.tw. or triamcinolone.tw. or prednisolone.tw. or prednisone.tw.
27. or/24–26
28. exp *expectorants/ or “##‘Mucolytic$’.mp.##”/ or “mucolytic$”.mp.
29. acetylcysteine.tw. or ambroxol.tw. or bromhexine.tw. or carbocysteine.tw. or dithiothreitol.tw.
30. guaiacol.tw. or “guaiacol glyceryl ether”.tw. or mesna.tw. or “potassium citrate”.tw.
31. “sodium acetate”.tw. or guaifenisen.tw.
32. or/28–31
33. physical therapies/
34. drainage, postural/
35. or/33–34
36. or/23,27,32,35
37. and/17,36
38. limit 37 to (human and english language and (adult < 19 to 44 years > or middle age < 45 to 64 years > or “aged < 65 and over >” or “aged, 80 and over”))

Treatment topic - Run in Cochrane Controlled Trials Register database 2/29/99 on 1998 Issue 4 of The Cochrane Library; updated quarterly (Update Software)

1. (((ACUTE OR EXACERBAT*) OR FLARE*) NEAR ((CHRONIC NEAR ((BRONCHIT* OR PULMONARY) OR LUNG)) OR (COPD OR COLD)))

NIPPV topic - Run in Ovid-MEDLINE <1966-February 1999> database on 2/22/99; updated weekly (Ovid for UNIX, Version 3.0, Release 7.8 Millennium, Ovid Technologies, Inc.)

1. exp *lung diseases, obstructive/ or “lung diseases, obstructive”.mp.
2. (copd or (chronic adj obstructive adj pulmonary adj disease) or (chronic adj bronchitis)).mp. [mp=title, abstract, registry number word, mesh subject heading]
3. 1 or 2
4. exp *Asthma/
5. 3 not 4
6. exp *intermittent positive-pressure ventilation/ or exp *positive-pressure respiration/ or exp *respiratory insufficiency/ or “nppv”.mp. or "nippv:.mp.
7. 5 and 6
8. limit 7 to (human and english language and (adult < 19 to 44 years > or middle age < 45 to 64 years > or “aged < 65 and over >” or “aged, 80 and over”))

All topics - run in Dialog version of EMBASE 1974-1999 (File 73) on 2/26/99; not updated (Elsevier Science B.V., 1999)

S1 CHRONIC(W)OBSTRUCTIVE(W)LUNG(W)DISEASE

S2 COPD OR (CHRONIC(W)OBSTRUCTIVE(W)PULMONARY(W)DISEASE) OR CHRONIC(W)BRONCHITIS

S3 S1 OR S2

S4 ASTHMA!

S5 S4/MAJ

S6 S3 NOT S5

S7 (ACUTE OR EXACERBAT? OR FLARE?)(6N)((CHRONIC(4N)(BRONCHIT? OR PULMONARY OR LUNG)) OR (COPD OR COLD))

S8 ACUTE OR EXACERBAT? OR FLARE?

S9 S6 AND S8

S10 S7 OR S9

S11 S10/ENG

S12 S11/HUMAN

S13 ADULT/DE

S14 AGED/DE

S15 S13 OR S14

S16 S12 AND S15

S17 POSITIVE(W)END(W)EXPIRATORY(W)PRESSURE

S18 POSITIVE(W)PRESSURE(W)(VENTILATION OR RESPIRATION)

S19 NPPV OR NIPPV

S20 S17 OR S18 OR S19

S21 S16 AND S20

S22 PROGNOS?

S23 DISEASE(N)COURSE

S24 PREDICT? OR SURVIVAL OR MORTALITY OR SENSITIVITY OR SPECIFICITY

S25 RESPIRATORY TRACT EXAMINATION!

S26 DI/DE

S27 S22 OR S23 OR S24 OR S25 OR S26

S28 S16 AND S27

S29 RANDOM? OR DOUBLE(W)BLIND OR PLACEBO? OR CLINICAL(W)TRIAL

S30 ANTIBIOTIC AGENT!

S31 S30/MAJ

S32 S29 NOT S31

S33 S16 AND S32

S34 BRONCHODILATING AGENT! OR GLUCOCORTICOID!

S35 EXPECTORANT AGENT! OR MUCOLYTIC AGENT!

S36 POSTURAL(W)DRAINAGE OR PHYSIOTHERAPY

S37 S34 OR S35 OR S36

S38 S33 AND S37