# References and Included Studies

1 Weiler JM, Bonini S, Coifman R, et al. American Academy of Allergy, Asthma & Immunology work group report: Exercise-induced asthma. J Allergy Clin Immunol. 2007;119(6):1349-58. [pmid: 17433829].
2 Godfrey S, Bar-Yishay E. Exercise-induced asthma revisited. Resp Med. 1993;162(87):331-44.
3 Tan RA, Spector SL. Exercise-induced asthma: diagnosis and management. Ann Allergy Asthma Immunol. 2002;89(3):226-35. [pmid: 12269641].
4 Randolph C. Making the diagnosis of asthma in the athlete. Clin Rev Allergy Immunol. 2005;29(2):113-23. [pmid: 16251765].
5 National Center for Health Statistics. National health interview survey 1982–1996. Atlanta. Centers for Disease Control. 2007.
6 Mehta H, Busse WW. Prevalence of exercise- induced asthma in the athlete. Weiler JM, editor. Allergic and respiratory disease in sports medicine. New York. Marcel Dekker Inc. 1997:81-6.
7 Rundell KW JD. Exercise-induced bronchospasm in the elite athlete. Sports Med. 2002;32(9):583-600. [pmid: 12096931].
8 Randolf C. Exercise-induced asthma: update on pathophysiology, clinical diagnosis and treatment. Curr Probl Pediatr. 1997;27(2):53-71. [pmid: 9059761].
9 Helenius I, Haahtela T. Allergy and asthma in elite summer sports athletes. J Allergy Clin Immunol. 2000;106:444-52. [pmid: 10984362].
10 Butz AM, Alexander C. Anxiety in children with asthma. J Asthma. 1993;30:199-209. [pmid: 8325829].
11 Whiting J, Rutjes AW, Dinnes J. Development and validation of methods for assessing the quality of diagnostic accuracy studies. Health Tech Assess. 2004;8(25).
12 Jadad AR, Moore RA, Carroll D. Assessing the quality of reports of randomized controlled trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
13 Schulz KF, Chalmers I, Hayes RJ. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatement effects in controlled trials. JAMA. 1995;273(5):408-12. [pmid: 7823387].
14 Altman D, Schulz K. Concealing treatment allocation in randomised trials. Br Med J. 2001;326:446-7. [pmid: 11520850].
15 Schunemann HJ, Oxman AD, Brozek J, et al. Grading quality of evidence and strength of recommendations for diagnostic tests and strategies. BMJ. 2008;336(7653):1106-10. [pmid: 18483053].
16 Owens DK, Lohr KN, Atkins D, Treadwell JR, et al. Grading the strength of a body of evidence when comparing medical interventions. Agency for Healthcare Research and Quality. 2008. Accessed: 2009 Sep 15. Available from: URL: http://www.effectivehealthcare.ahrq.gov/repFiles/2009_0805_grading.pdf.
17 Higgins JPT, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-58. [pmid: 12111919].
18 Crapo RO, Casaburi R, Coates AL, et al. Guidelines for methacholine and exercise challenge testing 1999. Am J Respir Crit Care Med. 2000;161(1):309-29. [pmid: 10619836].
19 Rundell KW, Slee JB. Exercise and other indirect challenges to demonstrate asthma or exercise- induced bronchoconstriction in athletes. J Allergy Clin Immunol. 2008;122(2):238-46. [pmid: 18678339].
20 Anderson SD, Holzer K. Exercise-induced asthma: is it the right diagnosis in elite athletes?. J Allergy Clin Immunol. 2000;106(3):419-28. [pmid: 10984359].
21 Frobase JF, Kyle JM, Hanna SD, et al. Sensitivity of post exercise cough in predicting exercise induced bronchospasm in young athletes [abstract]. Med Sci Sports Exerc. 1992;24(5 Suppl):S143.
22 Rupp NT, Brudno DS, Guill MF. The value of screening for risk of exercise-induced asthma in high school athletes. Ann Allergy. 1993;70(4):339-42. [pmid: 8466100].
23 Anderson SD, Charlton B, Weiler JM, et al. Comparison of mannitol and methacholine to predict exercise-induced bronchoconstriction and a clinical diagnosis of asthma. Respir Res. 2009;10:4. [pmid: 19161635].
24 Avital A, Novisky N, Bar-Yishay E, et al. Sensitivity of exercise and methacholine challenge tests in the detection of bronchial hyperreactivity in asthmatic children. Am Rev Respir Dis. 1989;139(4 Pt 2):A563.
25 Avital A, Godfrey S, Springer C. Exercise, methacholine, and adenosine 5′-monophosphate challenges in children with asthma: relation to severity of the disease. Pediatr Pulmonol. 2000;30(3):207-14. [pmid: 10973039].
26 Chatham M, Bleecker ER, Smith PL, et al. A comparison of histamine, methacholine, and exercise airway reactivity in normal and asthmatic subjects. Am Rev Respir Dis. 1982;126(2):235-40. [pmid: 7103250].
27 Clough JB, Hutchinson SA, Williams JD, et al. Airway response to exercise and methacholine in children with respiratory symptoms. Arch Dis Child. 1991;66(5):579-83. [pmid: 2039245].
28 Eggleston PA. A comparison of the asthmatic response to methacholine and exercise. J Allergy Clin Immunol. 1979;63(2):104-10. [pmid: 759463].
29 Foresi A, Mattoli S, Corbo GM, et al. Comparison of bronchial responses to ultrasonically nebulized distilled water, exercise, and methacholine in asthma. Chest. 1986;90(6):822-6. [pmid: 3536341].
30 Henriksen AH, Tveit KH, Holmen TL, et al. A study of the association between exercise- induced wheeze and exercise versus methacholine-induced bronchoconstriction in adolescents. Pediatr Allergy Immunol. 2002;13(3):203-8. [pmid: 12144643].
31 Kiviloog J. Bronchial reactivity to exercise and metacholine in bronchial asthma. Scand J Respir Dis. 1973;54(6):347-58. [pmid: 4773704].
32 Koh YY, Lim HS, Min KU, et al. Maximal airway narrowing on the dose-response curve to methacholine is increased after exercise-induced bronchoconstriction. J Asthma. 1996;33(1):55-65. [pmid: 8621372].
33 Lin CC, Wu JL, Huang WC, et al. A bronchial response comparison of exercise and methacholine in asthmatic subjects. J Asthma. 1991;28(1):31-40. [pmid: 2010426].
34 Pedersen L, Winther S, Backer V, et al. Airway responses to eucapnic hyperpnea, exercise, and methacholine in elite swimmers. Med Sci Sports Exerc. 2008;40(9):1567-72. [pmid: 18685536].
35 Sekerel BE, Saraclar Y, Kalayci O, et al. Comparison of four different measures of bronchial responsiveness in asthmatic children. Allergy. 1997;52(11):1106-9. [pmid: 9404563].
36 Souza ACTG, Pereira CAC. Bronchial provocation tests using methacholine, cycle ergometer exercise and free running in children with intermittent asthma. J Pediatr (Rio J). 2005;81(1):65-72. [pmid: 15742089].
37 Verges S, Devouassoux G, Flore P, et al. Bronchial hyperresponsiveness, airway inflammation, and airflow limitation in endurance athletes. Chest. 2005;127(6):1935-41. [pmid: 15947305].
38 Castricum A, Holzer K, Brukner P, et al. The role of the bronchial provocation challenge tests in the diagnosis of exercise induced bronchoconstriction in elite swimmers. Br J Sports Med. 2008.
39 Dickinson JW, Whyte GP, McConnell AK, et al. Screening elite winter athletes for exercise induced asthma: a comparison of three challenge methods. Br J Sports Med. 2006;40(2):179-82. [pmid: 16432008].
40 Reggiani E, Marugo L, Delpino A, et al. A comparison of various exercise challenge tests on airway reactivity in atopical swimmers. J Sports Med Phys Fitness. 1988;28(4):394-401. [pmid: 3230927].
41 Rundell KW, Wilber RL, Szmedra L, et al. Exercise-induced asthma screening of elite athletes: field versus laboratory exercise challenge. Med Sci Sports Exerc. 2000;32(2):309-16. [pmid: 10694112].
42 Eliasson AH, Phillips YY, Rajagopal KR, et al. Sensitivity and specificity of bronchial provocation testing. An evaluation of four techniques in exercise-induced bronchospasm. Chest. 1992;102(2):347-55. [pmid: 1643912].
43 Rosenthal RR. Simplified eucapnic voluntary hyperventilation challenge. J Allergy Clin Immunol. 1984;73(5 Pt 2):676-9. [pmid: 6425390].
44 Rundell KW, Spiering BA, Baumann JM, et al. Effects of montelukast on airway narrowing from eucapnic voluntary hyperventilation and cold air exercise. Br J Sports Med. 2005;39(4):232-6. [pmid: 15793094].
45 Schmidt A, Bach-Mortensen N, Bundgaard A. Comparison of isocapnic hyperventilation and treadmill exercise in children with exercise induced asthma. Scand J Clin Lab Invest. 1983;43(3):203-6. [pmid: 6622967].
46 Garcia de la Rubia S, Pajaron-Fernandez MJ, Sanchez-Solis M, et al. Exercise-induced asthma in children: a comparative study of free and treadmill running. Ann Allergy Asthma Immunol. 1998;80(3):232-6. [pmid: 9532971].
47 Brannan JD, Koskela H, Anderson SD, et al. Responsiveness to mannitol in asthmatic subjects with exercise- and hyperventilation-induced asthma. Am J Respir Crit Care Med. 1998;158(4):1120-6. [pmid: 9769270].
48 Anderson SD, Sue-Chu M, Perry CP, et al. Bronchial challenges in athletes applying to inhale a beta2-agonist at the 2004 Summer Olympics. J Allergy Clin Immunol. 2006;117(4):767-73. [pmid: 16630932].
49 Anderson SD, Argyros GJ, Magnussen H, et al. Provocation by eucapnic voluntary hyperpnoea to identify exercise induced bronchoconstriction [review] [30 refs]. Br J Sports Med. 2001;35(5):344-7. [pmid: 11579071].
50 Brannan JD, Gulliksson M, Anderson SD, et al. Inhibition of mast cell PGD2 release protects against mannitol-induced airway narrowing. Eur Respir J. 2006;27(5):944-50. [pmid: 16707393].
51 Brannan JD, Gulliksson M, Anderson SD, et al. Evidence of mast cell activation and leukotriene release after mannitol inhalation. Eur Respir J. 2003;22(3):491-6. [pmid: 14516140].
52 Kersten ET, Driessen JM, van der Berg JD, et al. Mannitol and exercise challenge tests in asthmatic children. Pediatr Pulmonol. 2009;44(7):655-61. [pmid: 19499571].
53 Edelman JM, Turpin JA, Bronsky EA, et al. Oral montelukast compared with inhaled salmeterol to prevent exercise-induced bronchoconstriction. A randomized, double-blind trial. Ann Intern Med. 2000;132(2):97-104. [pmid: 10644288].
54 Garcia R, Guerra P, Feo F, et al. Tachyphylaxis following regular use of formoterol in exercise-induced bronchospasm. J Investig Allergol Clin Immunol. 2001;11(3):176-82.
55 Nelson JA, Strauss L, Skowronski M, et al. Effect of long-term salmeterol treatment on exercise-induced asthma. N Engl J Med. 1998;339(3):141-6. [pmid: 9664089].
56 Pearlman D, Qaqundah P, Matz J, et al. Fluticasone propionate/salmeterol and exercise-induced asthma in children with persistent asthma. Pediatr Pulmonol. 2009;44(5):429-35. [pmid: 19382218].
57 Ramage L, Lipworth BJ, Ingram CG, et al. Reduced protection against exercise induced bronchoconstriction after chronic dosing with salmeterol. Respir Med. 1994;88(5):363-8. [pmid: 7913549].
58 Selvaggio D, Gagliardini R, Franceschini F, et al. Intermittent administration of salmeterol does not induce tolerance to the bronchoprotective effect in exercise induced bronchoconstriction [abstract]. Eur Respir J. 2003;22(Suppl 45):3117.
59 Simons FE, Gerstner TV, Cheang MS. Tolerance to the bronchoprotective effect of salmeterol in adolescents with exercise-induced asthma using concurrent inhaled glucocorticoid treatment. Pediatrics. 1997;99(5):655-9. [pmid: 9113940].
60 Villaran C, O’Neill SJ, Helbling A, et al. Montelukast versus salmeterol in patients with asthma and exercise-induced bronchoconstriction. Montelukast/Salmeterol Exercise Study Group. J Allergy Clin Immunol. 1999;104(3):547-53. [pmid: 10482826].
61 Weiler JM, Nathan RA, Rupp NT, et al. Effect of fluticasone/salmeterol administered via a single device on exercise-induced bronchospasm in patients with persistent asthma. Ann Allergy Asthma Immunol. 2005;94(1):65-72. [pmid: 15702819].
62 Hancox RJ, Subbarao P, Kamada D, et al. Beta2-agonist tolerance and exercise-induced bronchospasm. Am J Respir Crit Care Med. 2002;165(8):1068-70. [pmid: 11956046].
63 Inman MD, O’Byrne PM. The effect of regular inhaled albuterol on exercise-induced bronchoconstriction. Am J Respir Crit Care Med. 1996;153(1):65-9. [pmid: 8542164].
64 Becker AB, Watson WTA, Simons FER, et al. Onset of protection from exercise-induced bronchoconstriction (EIB) by montelukast in children with asthma [abstract]. Am J Respir Crit Care Med. 2002;165(Suppl 8):B44.
65 Coreno A, Skowronski M, Kotaru C, et al. Comparative effects of long-acting beta_2_- agonists, leukotriene receptor antagonists, and a 5-lipoxygenase inhibitor on exercise-induced asthma. J Allergy Clin Immunol. 2000;106(3):500-6. [pmid: 10984370].
66 Mastalerz L, Gawlewicz-Mroczka A, Cmiel A, et al. Protection against exercise-induced bronchoconstriction by montelukast in aspirin-sensitive and aspirin-tolerant patients with asthma. Clin Exp Allergy. 2002;32(9):1360-5. [pmid: 12220476].
67 Pearlman DS, Ostrom NK, Bronsky EA, et al. The leukotriene D4-receptor antagonist zafirlukast attenuates exercise-induced bronchoconstriction in children. J Pediatr. 1999;134(3):273-9. [pmid: 10064661].
68 Pearlman DS, van Adelsberg J, Philip G, et al. Onset and duration of protection against exercise-induced bronchoconstriction by a single oral dose of montelukast. Ann Allergy Asthma Immunol. 2006;97(1):98-104. [pmid: 16892789].
69 Peroni DG, Piacentini GL, Pietrobelli A, et al. The combination of single-dose montelukast and loratadine on exercise-induced bronchospasm in children. Eur Respir J. 2002;20(1):104-7. [pmid: 12166555].
70 Philip G, Pearlman DS, Villarán C, et al. Single- dose montelukast or salmeterol as protection against exercise-induced bronchoconstriction. Chest. 2007;132(3):875-83. [pmid: 17573489].
71 Philip G, Villaran C, Pearlman DS, et al. Protection against exercise-induced bronchoconstriction two hours after a single oral dose of montelukast. J Asthma. 2007;44(3):213-7. [pmid: 17454341].
72 Hills EA, Davies S, Geary M. The effect of betamethasone valerate aerosol in exercise-induced asthma. Postgrad Med J. 1974;50(Suppl 4):67-8. [pmid: 4219630].
73 Hodgson SV, McPherson A, Friedman M. The effect of betamethasone valerate aerosol on exercise-induced asthma in children. Postgrad Med J. 1974;50(Suppl 4):69-73. [pmid: 4619448].
74 Thio BJ, Slingerland GL, Nagelkerke AF, et al. Effects of single-dose fluticasone on exercise-induced asthma in asthmatic children: a pilot study. Pediatr Pulmonol. 2001;32(2):115-21. [pmid: 11477728].
75 Venge P, Henriksen J, Dahl R, et al. Exercise- induced asthma and the generation of neutrophil chemotactic activity. J Allergy Clin Immunol. 1990;85(2):498-504. [pmid: 2105990].
76 Spooner CH, Saunders LD, Rowe BH. Nedocromil sodium for preventing exercise-induced bronchoconstriction. Cochrane Database Syst Rev. 2002;1:CD001183. [pmid: 11869595].
77 Kelly K, Spooner CH, Rowe BH. Nedocromil sodium vs. sodium cromoglycate for preventing exercise-induced bronchoconstriction in asthmatics. Cochrane Database Syst Rev. 2000;4:CD002731. [pmid: 11034750].
78 Spooner CH, Spooner GH, Rowe BH. Mast-cell stabilising agents to prevent exercise-induced bronchoconstriction. Cochrane Database Syst Rev. 2003;4:CD002307. [pmid: 14583951].
79 Boner AL, Antolini I, Andreoli A, et al. Comparison of the effects of inhaled calcium antagonist verapamil, sodium cromoglycate and ipratropium bromide on exercise-induced bronchoconstriction in children with asthma. Eur J Pediatr. 1987;146(4):408-11. [pmid: 2958282].
80 Borut TC, Tashkin DP, Fischer TJ, et al. Comparison of aerosolized atropine sulfate and SCH 1000 on exercise-induced bronchospasm in children. J Allergy Clin Immunol. 1977;60(2):127-33. [pmid: 141471].
81 Boulet LP, Turcotte H, Tennina S. Comparative efficacy of salbutamol, ipratropium, and cromoglycate in the prevention of bronchospasm induced by exercise and hyperosmolar challenges. J Allergy Clin Immunol. 1989;83(5):882-7. [pmid: 2523921].
82 Bundgaard A, Rasmussen FV, Madsen L. Pretreatment of exercise-induced asthma in adults with aerosols and pulverized tablets. Allergy. 1980;35(8):639-45. [pmid: 6452833].
83 Chan-Yeung M. The effect of Sch 1000 and disodium cromoglycate on exercise-induced asthma. Chest. 1977;71(3):320-3. [pmid: 138577].
84 Chen WY, Brenner AM, Weiser PC, et al. Atropine and exercise-induced bronchoconstriction. Chest. 1981;79(6):651-6. [pmid: 7226953].
85 Dorward AJ, Patel KR. A comparison of ketotifen with clemastine, ipratropium bromide and sodium cromoglycate in exercise-induced asthma. Clin Allergy. 1982;12(4):355-61. [pmid: 6214337].
86 Godfrey S, Konig P. Inhibition of exercise-induced asthma by different pharmacological pathways. Thorax. 1976;31(2):137-43. [pmid: 821168].
87 Hartley JP, Davies BH. Cholinergic blockade in the prevention of exercise-induced asthma. Thorax. 1980;35(9):680-5. [pmid: 6449753].
88 Larsson K. Oxitropium bromide, ipratropium bromide and fenoterol in exercise-induced asthma. Respiration. 1982;43(1):57-63. [pmid: 6211753].
89 Neijens HJ, Wesselius T, Kerrebijn KF. Exercise-induced bronchoconstriction as an expression of bronchial hyperreactivity: a study of its mechanisms in children. Thorax. 1981;36(7):517-22. [pmid: 6797085].
90 Poppius H, Sovijarvi AR, Tammilehto L. Lack of protective effect of high-dose ipratropium on bronchoconstriction following exercise with cold air breathing in patients with mild asthma. Eur J Respir Dis. 1986;68(5):319-25. [pmid: 2942416].
91 Tashkin DP, Katz RM, Kerschnar H, et al. Comparison of aerosolized atropine, isoproterenol, atropine plus isoproterenol, disodium cromoglycate and placebo in the prevention of exercise-induced asthma. Ann Allergy. 1977;39(5):311-8. [pmid: 411398].
92 Taytard A, Vergeret J, Guenard H, et al. Prevention of exercise-induced asthma by oxitropium bromide. Eur J Clin Pharmacol. 1987;33(5):455-8. [pmid: 3428339].
93 Thomson NC, Patel KR, Kerr JW. Sodium cromoglycate and ipratropium bromide in exercise-induced asthma. Thorax. 1978;33(6):694-9. [pmid: 154747].
94 Tullett WM, Patel KR, Berkin KE, et al. Effect of lignocaine, sodium cromoglycate, and ipratropium bromide in exercise-induced asthma. Thorax. 1982;37(10):737-40. [pmid: 6218645].
95 Wolkove N, Kreisman H, Frank H, et al. The effect of ipratropium on exercise-induced bronchoconstriction. Ann Allergy. 1981;47(5 Pt 1):311-5. [pmid: 6459045].
96 Yeung R, Nolan GM, Levison H. Comparison of the effects of inhaled SCH 1000 and fenoterol on exercise-induced bronchospasm in children. Pediatrics. 1980;66(1):109-14. [pmid: 6447269].
97 De Bisschop C, Guenard H, Desnot P, et al. Reduction of exercise-induced asthma in children by short, repeated warm ups. Br J Sports Med. 1999;33(2):100-4. [pmid: 10205690].
98 Eck R, Lachtermann E, Pleyer K, et al. Effect of standardized warm-up programs on the intensity and frequency of exercise induced asthma (EIA) in children and teenagers. Int J Sports Med. 2002;23(Suppl):S86.
99 McKenzie DC, McLuckie SL, Stirling DR. The protective effects of continuous and interval exercise in athletes with exercise-induced asthma. Med Sci Sports Exerc. 1994;26(8):951-6. [pmid: 7968428].
100 Mickleborough TD, Lindley MR, Turner LA. Comparative effects of a high-intensity interval warm-up and salbutamol on the bronchoconstrictor response to exercise in asthmatic athletes. Int J Sports Med. 2007;28(6):456-62. [pmid: 17111314].
101 Morton AR, Fitch KD, Davis T. The effect of "warm-up" on exercise-induced asthma. Ann Allergy. 1979;42(4):257-60. [pmid: 434587].
102 Reiff DB, Choudry NB, Pride NB, et al. The effect of prolonged submaximal warm-up exercise on exercise-induced asthma. Am Rev Respir Dis. 1989;139(2):479-84. [pmid: 2913893].
103 Schnall RP, Landau LI. Protective effects of repeated short sprints in exercise-induced asthma. Thorax. 1980;35(11):828-32. [pmid: 7221978].
104 Spooner CH, Rowe BH, Saunders LD. Nedocromil sodium in the treatment of exercise-induced asthma: a meta-analysis. Eur Respir J. 2000;16(1):30-7. [pmid: 10933081].
105 Bossuyt PM, Reitsma JB, Bruns DE, et al. The STARD statement for reporting studies of diagnostic accuracy: explanation and elaboration. Ann Intern Med. 2003;138(1):W1-12. [pmid: 12513067].
106 Altman DG, Schulz KF, Moher D, et al. The revised CONSORT statement for reporting randomized trials: explanation and elaboration. Ann Intern Med. 2001;134(8):663-94. [pmid: 11304107].
107 Koh MS, Tee A, Lasserson TJ, et al. Inhaled corticosteroids compared to placebo for prevention of exercise induced bronchoconstriction. Cochrane Database Syst Rev. 2007;3:CD002739. [pmid: 17636704].
108 Virant FS. The history of exercise-induced asthma and definition of the syndrome. Weiler JM, editor. Allergic and respiratory disease in sports medicine. New York. Marcel Dekker, Inc. 1997:65-80.
109 Global Initiative for Asthma (GINA). Global strategy for asthma management and prevention. http://www.ginasthma.org. 2007. [Accessed: 2008 May 1]. Available from: URL: http://www.ginasthma.com/Guidelineitem.asp?|1=2&I2=1&intld=1389.
110 Randolph CC. Allergic rhinitis and asthma in the athlete. Allergy Asthma Proc. 2006;27(2):104-9. [pmid: 16724626].
111 Backer V, Lund T, Pedersen L. Pharmaceutical treatment of asthma symptoms in elite athletes - doping or therapy?. Scand J Med Sci Sports. 2007;17(6):615-22. [pmid: 18093034].
112 Chan-Yeung MM, Vyas MN, Grzybowski S. Exercise-induced asthma. Am Rev Respir Dis. 1971;104(6):915-23. [pmid: 5125592].
113 Anderson SD, Daviskas E. Pathophysiology of exercise-induced asthma: the role of respiratory water loss in allergic and respiratory disease. Weiler JM, editor. Allergic and respiratory disease in sports medicine. New York. Marcel Dekker, Inc. 1997:87-114.
114 McFadden ER Jr, Lenner KA, Strohl KP. Postexertional airway rewarming and thermally induced asthma. New insights into pathophysiology and possible pathogenesis. J Clin Invest. 1986;78(1):18-25. [pmid: 3722374].
115 McFadden ER Jr, Nelson JA, Skowronski ME, et al. Thermally induced asthma and airway drying. Am J Respir Crit Care Med. 1999;160(1):221-6. [pmid: 10390404].
116 Anderson SD. Issues in exercise-induced asthma. J Allergy Clin Immunol. 1985;76(6):763-72. [pmid: 2999208].
117 Deal EC Jr, McFadden ER Jr, Ingram RH Jr, et al. Hyperpnea and heat flux: initial reaction sequence in exercise-induced asthma. J Appl Physiol. 1979;46(3):476-83. [pmid: 438015].
118 McFadden ER, Gilbert IA. Current concepts: exercise-induced asthma. NEJM. 1994;330(19):1362-7. [pmid: 8152449].
119 Virant FS. Exercise-induced bronchospasm: epidemiology, pathophysiology, and therapy. Med Sci Sports Exerc. 1992;24:851-5. [pmid: 1406168].
120 Hogshead N, Couzens G. Asthma and exercise. New York. Henry Holt and Company. 1989.
121 Suman OE, Beck KC, Babcock MA, et al. Airway obstruction during exercise and isocapnic hyperventilation in asthmatic subjects. J Appl Physiol. 1999;87(3):1107-13. [pmid: 10484584].
122 Anderson SD. Specific problems: exercise-induced asthma. O’Byrne P, Thomson NC, editors. Manual of asthma management. London. WB Saunders Co. Ltd. 1995:641-3.
123 Anderson SD, Schoeffel RE, Black JL, et al. Airway cooling as the stimulus to exercise-induced asthma: a re-evaluation. Eur J Respir Dis. 1985;67(1):20-30. [pmid: 4054253].
124 Deal ECJ, McFadden ERJ, Ingram RHJ. Airway responsiveness to cold air and hyperpnea in normal subjects in the nose with hayfever and asthma. Am Rev Respir Dis. 1980;121:621-8. [pmid: 7386975].
125 Freed AN. Models and mechanisms of exercise-induced asthma. Eur Respir J. 1995;8(10):1770-85. [pmid: 8586137].
126 Mellion MB, Kobayashi RH. Exercise-induced asthma. Am Family Physician. 1992;45:2671.
127 Proctor NH, Hughes JP, Wesenberg GL. Chlorine. Proctor NH, Hughes JP, editors. Chemical hazards of the workplace. Philadelphia. Lippincot. 1978:157-8.
128 Morton AR, Hahn AG, Fitch KD. Continuous and intermittent running in the provocation of asthma. Ann Allergy. 1982;48(2):123-9. [pmid: 7065468].
129 Wilson BA, Evans JN. Standardization of work intensity for evaluation of exercise-induced bronchoconstriction. Eur J Appl Physiol. 1981;48:189-94.
130 Hendrickson CD, Lynch JM, Gleeson K. Exercise induced asthma: a clinical perspective. Lung. 1993;172:1-14. [pmid: 7905038].
131 National Center for Health Statistics. Report of final mortality statistics 1979–1998. Atlanta. Centers for Disease Control. 2007.
132 National Center for Health Statistics. National ambulatory medical care survey 1992–2004. Atlanta. Centers for Disease Control. 2007.
133 Rupp NT. Diagnosis and management of exercise-induced asthma. Phys Sportsmed. 1996;24(1):77-87. [pmid: 20086954].
134 Haahtela T, Larsson K, Bonini S. Epidemiology of asthma, allergy and bronchial hyperresponsiveness in sports. Carlsen K-H, Delgado L, Del Giacco S, editors. Diagnosis, prevention and treatment of exercise-related asthma, respiratory and allergic disorders in sports. Wakefield, UK. European Respiratory Society Journals Ltd. 2005:1-4.
135 Bjermer L, Anderson SD. Bronchial hyperresponsiveness in athletes: mechanisms for development. Carlsen K-H, Delgado L, Del Giacco S, editors. Diagnosis, prevention and treatment of exercise-related asthma, respiratory and allergic disorders in sports. Wakefield, UK. European Respiratory Society Journals Ltd. 2005:19-34.
136 Price B. The asthma experience: altered body image and non-compliance. J Clin Nurs. 1994;3:139-45. [pmid: 7834128].
137 Padur JS, Rapoff MA, Houston BK, et al. Psychosocial adjustment and the role of functional status for children with asthma. J Asthma. 1995;32:345-53. [pmid: 7559275].
138 Nastasi KJ, Henly TL, Blaiss MS. Exercise- induced asthma and the athlete. J Asthma. 1995;32:249-57. [pmid: 7629000].
139 Becker JM, Rogers J, Rossini G, et al. Asthma deaths during sports: report of a 7-year experience. J Allergy Clin Immunol. 2004;113(2):264-7. [pmid: 14767440].
140 Anderson SD, Brusasco V, Haahtela T, et al. Criteria for diagnosis of asthma, EIB and AHR for athletes: lessons from the Olympic games. Carlsen K-H, Delgado L, Del Giacco S, editors. Diagnosis, prevention and treatment of exercise-related asthma, respiratory and allergic disorders in sports. Wakefield, UK. European Respiratory Society Journals Ltd. 2005:44-66.
141 Kattan M, Keens TG, Mellis CM. The response to exercise in normal and asthmatic children. J Pediatr. 1978;92:718-21. [pmid: 641618].
142 Roca J, Whipp BJ, Agusti AGN. Clinical exercise testing with reference to lung diseases: indications, standardizations and interpretation strategies. Position document of the European Respiratory Society. Eur Respir J. 1997;10:2662-89. [pmid: 9426113].
143 Crapo RO, Hankinson JL, Irvin C. Standardization of spirometry. 1994 update. The official statement of the American Thoracic Society. Am J Respir Crit Care Med. 1994;152:1107-36.
144 Helenius IJ, Tikkanen HO, Haahtela T. Occurrence of exercise induced bronchospasm in elite runners: dependence on atopy and exposure to cold air and pollen. Br J Sports Med. 1998;32:125-9. [pmid: 9631218].
145 Rundell KW, Im J, Mayers LB, et al. Self-reported symptoms and exercise-induced asthma in the elite athlete. Med Sci Sports Exerc. 2001;33:208-13. [pmid: 11224807].
146 Hurwitz KM, Argyros GJ, Roach JM, et al. Interpretation of eucapnic voluntary hyperventilation in the diagnosis of asthma. Chest. 1995;108:1240-5. [pmid: 7587423].
147 Eggleston PA. Methods of exercise challenge. J Allergy Clin Immunol. 1984;73:666-9. [pmid: 6715731].
148 Godfrey S, Konig P. Suppression of exercise-induced asthma by salbutamol, theophylline, atropine, cromolyn, and placebo in a group of asthmatic children. Pediatrics. 1975;56(5 pt-2 suppl):930-4. [pmid: 810767].
149 Joppich R. Comparison of the effects of reproterol, oxitropium bromide, disodium cromoglycate and theophylline in the prevention of exercise-induced asthma in children. Atemwegs- und Lungenkrankheiten. 1987;13(9):453-6.
150 Shapiro GG, McPhillips JJ, Smith K, et al. Effectiveness of terbutaline and theophylline alone and in combination in exercise-induced bronchospasm. Pediatrics. 1981;67(4):508-13. [pmid: 7019839].
151 Leech S, Wolfson K, Burns R. Ketotifen vs. disodium cromoglycate DSCG in the prophylaxis of exercise-induced asthma EIA. Ann Allergy. 1983;50:352.
152 Gmur H, Scherrer M. Protection from exertion- induced bronchial asthma with disodium cromoglycate DSCG cromolyn, lomudal, intal and with ketotifen zaditen. Doubly crossed double-blind study. Schweiz Med Wochenschr. 1979;109:881-4. [pmid: 109916].
153 Tan WC, Lim TK. Double-blind comparison of the protective effect of sodium cromoglycate and ketotifen on exercise-induced asthma in adults. Allergy. 1987;42(4):315-7. [pmid: 3113280].
154 Rampulla C, Bruschi C, Zoia MC. Calcium-antagonists and exercise-induced bronchoconstriction (EIB): Immediate and late effects of nifedipine, in comparison with salbuamol and DSCG. Folia Allergologica et Immunologica Clinica. 1985;32(4):271-7.
155 Sin HL, Jae JS, Sang YL, et al. The protective effect of inhaled heparin, cromolyn, budesonide, and furosemide on exercise-induced asthma. Zhonghua Jie He He Hu Xi Za Zhi. 1998;45(6):1188-98.
156 Novembre E, Frongia G, Lombardi E, et al. The preventive effect and duration of action of two doses of inhaled furosemide on exercise-induced asthma in children. J Allergy Clin Immunol. 1995;96(6 Pt 1):906-9. [pmid: 8543748].
157 Novembre E, Frongia G, Lombardi E, et al. The preventive effect of nedocromil or furosemide alone or in combination on exercise-induced asthma in children. J Allergy Clin Immunol. 1994;94(2 Pt 1):201-6. [pmid: 8064072].
158 Melo RE, Sole D, Naspitz CK. Comparative efficacy of inhaled furosemide and disodium cromoglycate in the treatment of exercise-induced asthma in children. J Allergy Clin Immunol. 1997;99(2):204-9. [pmid: 9042046].
159 Cho MK, Bero LA. The quality of drug studies in symposium proceedings. Ann Int Med. 1996;124:485-9. [pmid: 8602706].
160 Deeks JJ, Altman DG, Bradburn MJ. Statistical methods for examining heterogeneity and combining results from several studies in meta-analysis. Egger M, Davey Smith G, Altman DG, editors. Systematic reviews in health care: meta-analysis in context. 2nd ed. London. BMJ Publishing Group. 2001:285-312.
161 Kelly K, Spooner CH, Rowe BH. Nedocromil sodium versus sodium cromoglycate in treatment of exercise-induced bronchoconstriction: a systematic review. Eur Respir J. 2001;17(1):39-45. [pmid: 11307752].
162 Compendium of pharmaceuticals and specialties. 9th ed. Ottawa, ON. Canadian Pharmacists Association. 2008.
163 Oseid S, Mellbye E, Hem E. Effect of nedocromil sodium on exercise-induced bronchoconstriction exacerbated by inhalation of cold air. Scand J Med Sci Sports. 1995;5(2):88-93. [pmid: 7606516].
164 Palange P, Ward SA, Carlsen K-H, et al. Recommendations on the use of exercise testing in clinical practice. Eur Respir J. 2007;29:185-209. [pmid: 17197484].
165 Aaron SD, Vandemheen KL, Boulet LP, et al. Overdiagnosis of asthma in obese and nonobese adults. CMAJ. 2008;179(11):1121-31. [pmid: 19015563].
166 Sterling GM. The mechanism of bronchoconstriction due to hypocapnia in man. Clin Sci. 1968;34(2):277-85. [pmid: 5653688].
167 Leeflang MM, Deeks JJ, Gatsonis C, et al. Systematic reviews of diagnostic test accuracy. Ann Intern Med. 2008;149(12):889-97. [pmid: 19075208].
168 McDonald NJ, Bara AI. Anticholinergic therapy for chronic asthma in children over two years of age. Cochrane Database Syst Rev. 2003;3:CD003535. [pmid: 12917970].
169 Westby M, Benson M, Gibson P. Anticholinergic agents for chronic asthma in adults. Cochrane Database Syst Rev. 2004;3:CD003269. [pmid: 15266477].
170 Uboweja A, Malhotra S, Pandhi P. Effect of inhaled corticosteroids on risk of development of cataracts: a meta-analysis. Fundam Clin Pharmacol. 2006;20(3):305-9. [pmid: 16671966].
171 Halpern MT, Schmier JK, Van Kerkhove MD, et al. Impact of long-term inhaled corticosteroid therapy on bone mineral density: results of a meta-analysis. Ann Allergy Asthma Immunol. 2004;92:201-7. [pmid: 14989387].
172 Ducharme FM, Lasserson TJ, Cates CJ. Long-acting beta2-agonists versus antileukotrienes as add-on therapy to inhaled corticosteroids for chronic asthma. Cochrane Database Syst Rev. 2006;4:CD003137. [pmid: 17054161].