# Discussion

## Diagnostic Test Accuracy Review

A valid test to determine if EIB or EIA is present must involve a standardized measure of effort (heart rate or ventilation rate) or dose of inhalant and be of sufficient duration to produce a response in susceptible subjects. Airway response measures must also be standardized. Testing protocols for airway constriction can be classified into direct or indirect tests. Indirect challenges such as exercise, eucapnic voluntary hyperpnea (EVH), and inhaled mannitol are thought to cause inflammatory cells to release mediators such as leukotrienes, prostaglandin, and histamine which provoke smooth muscle constriction.20 In contrast, direct tests such as methacholine or histamine act directly on smooth muscle receptors to cause constriction independent of airway inflammation.19

Using a comprehensive search strategy and concerted efforts to avoid publication and selection bias, this review identified all the available evidence to assess the diagnostic test characteristics of six tests for the diagnosis of EIB/EIA. In total, we identified 27 studies that met our inclusion criteria. The number of studies available to address each of the six key questions ranged from 2 to 16.

There are many methodological considerations when undertaking a systematic review of the diagnostic literature. To determine the accuracy of a diagnostic test, a reference standard must be available for comparison. The reference test used for this report was the exercise challenge test (ECT) as detailed by the ATS.18 The guidelines cover water content and temperature of the inspired air plus work effort required for either treadmill or bicycle ergometer testing. According to the ATS criteria,18 during the ECT participants should inspire dry air at a temperature of less than 25°C with a noseclip in place to force mouth breathing. Nasal breathing decreases the water loss from the airways. Temperature and relative humidity (RH) during testing should be documented, and RH should be low (50 percent or less). It is unclear if the ambient humidity in the typical air conditioned laboratory (30 to 50 percent water vapor saturation) is less likely to induce airway narrowing as compared with perfectly dry air obtained from compressed gas (i.e., RH ~0 percent).18 However, as airway drying is the primary trigger for EIB/EIA,19 it would seem logical that tests completed with compressed air would be more sensitive for detecting EIB/EIA. In this review, many studies had the participants inspire room air as detailed in ATS guidelines, while others used compressed air during their ECT.

Among the included studies, detailed reporting of the ECT protocol varied, and in several cases it was not clear if the challenge met ATS recommendations particularly when it came to nose versus mouth breathing, effort required, and duration. Treadmill grade and speed must be individually chosen and progressively increased in the first minutes to produce 6 to 8 minutes of near maximum target heart rates (i.e., 80 to 90 percent of the predicted rate for age). Ventilation should reach 40 to 60 percent of the predicted maximum voluntary ventilation. In a bicycle ergometer challenge a target work rate is determined to achieve target ventilation and the work rate is gradually increased until the target exercise intensity is maintained for 4 to 6 minutes. With either method, the subject must reach the target heart or ventilation rate in the first 4 minutes as water loss and airway drying determine the development of EIB/EIA.18 Since the specifics of the ECTs were not consistently reported in full, some exercise challenges may not have met these standards. Furthermore, a number of studies used higher diagnostic cutpoints of a 15 or 20 percent fall in FEV_1_ post-exercise instead of the ATS guideline of a 10 percent drop. We could not always extract results for the 10 percent cutpoint. We suspect that the variability in methodology used for the reference standard ECT may be the cause of some heterogeneity in comparisons with other EIB/EIA diagnostic methods.

A key concern, which may also have contributed to the heterogeneity observed across all the diagnostic comparisons, was that of a spectrum bias. Ideally, studies should have a sample of participants who are representative of the population being examined for EIB/EIA. That is, studies should have participants that span the range from high to low likelihood of EIB/EIA so that the true positive and true negative numbers are approximately the same. Many studies included in these reviews purposely recruited participants who either had or did not have a history of EIB/EIA or asthma (asthma increases the likelihood of having EIA) or they did not mention clinical history or provide baseline data. Cumulatively, only 6 percent of studies had a representative sample and only 21 percent stated their inclusion criteria. Virtually all studies recruited volunteers who were willing to undergo the tests being compared. The lack of a representative patient spectrum limits the generalizability of the results to the target population of people with suspected EIB/EIA and therefore a pooled estimate of sensitivity and specificity is not reliable.

Table 41 and the following sections review the individual tests examined in the review.

Table 41 Summary of sensitivity and specificity for the diagnostic test accuracy review

Index test | # studies, sample size | ECT type (# studies) Definition of EIB/EIA (# studies) | Sensitivity point estimate or range mean % (95% CI) | Specificity point estimate or range mean % (95% CI) | ECT +ve ( 10% fall FEV_1_) | Index test +ve | Evidence Grade
Index test | # studies, sample size | ECT type (# studies) Definition of EIB/EIA (# studies) | Sensitivity point estimate or range mean % (95% CI) | Specificity point estimate or range mean % (95% CI) | N (%) | N (%) | Evidence Grade
Self-report | 2, N=206 | Treadmill (2) ≥10% fall FEV_1_ (1) ≥15% fall FEV_1_ (1) | | | | | Very low
Self-report | 2, N=206 | Treadmill (2) ≥10% fall FEV_1_ (1) ≥15% fall FEV_1_ (1) | 89% (67, 99) | 86% (64, 97) | 19 (48) | 20 (50) | Very low
Self-report | 2, N=206 | Treadmill (2) ≥10% fall FEV_1_ (1) ≥15% fall FEV_1_ (1) | 36% (17, 59) | 85% (78, 90) | 20 (13) | 30 (18) | Very low
Methacholine | 16, N=1,048 | Treadmill (10) Bicycle ergometer (6) | ≥10% fall FEV_1_ | | | | Moderate
Methacholine | 16, N=1,048 | ECT: ≥8% fall FEV_1_ (1), ≥10% fall FEV_1_ (6), ≥15% fall FEV_1_ (2), ≥18% fall FEV_1_ (1), ≥20% fall FEV_1_ (5) | 0–100%; (MCH_PC20_ <8mg/ml) | 0–100% | 331 (57) | 416 (71) | Moderate
Methacholine | 16, N=1,048 | MCH: ≥20% fall FEV_1_ at various doses MCH | 55–100% (MCH_PC20_ <16mg/ml) | 0–100% | 420 (53) | 498 (63) | Moderate
Sport specific challenge | 5, N=95 | Treadmill (3), bicycle ergometer (2) ≥10% fall FEV_1_ (4) ≥20% fall FEV_1_ (1) | ≥10% fall FEV_1_ wim challenge0–50% | 83–100% | 11 (19) | 5 (9) | Low
Sport specific challenge | 5, N=95 | Treadmill (3), bicycle ergometer (2) ≥10% fall FEV_1_ (4) ≥20% fall FEV_1_ (1) | Winter sports n=37 00% ( 48–100) (1 study) | 79% (49, 95) (1 study) | 5 (14) | 26 (70) | Low
Eucapnic voluntary hyperpnea | 7, N=138 | Treadmill (4), bicycle ergometer (3) | ≥10% fall FEV_1_ | | | | Low
Eucapnic voluntary hyperpnea | 7, N=138 | ECT: ≥10% fall FEV_1_ (4), ≥20% fall FEV_1_ (1), NR (2) | 25–90% | 0–71% | 42 (30) | 74 (54) | Low
Eucapnic voluntary hyperpnea | 7, N=138 | EVH: ≥10% fall FEV_1_ (4), NR (3) | | | | | Low
FRAST | 3, N=99 | Treadmill (1), bicycle ergometer (2) ≥10% fall FEV_1_ (1) ≥20% fall FEV_1_ (2) | ≥10% fall FEV_1_: 60–67% | 47–67% | 13 (38) | 18 (53) | Very low
FRAST | 3, N=99 | Treadmill (1), bicycle ergometer (2) ≥10% fall FEV_1_ (1) ≥20% fall FEV_1_ (2) | ≥20% fall FEV_1_: 53% | 100% | 30 (50) | 16 (27) | Very low
Mannitol | 3, N=423 | Treadmill (2), bicycle ergometer (1) | ≥10% fall FEV_1_ | | | | Moderate
Mannitol | 3, N=423 | ECT: ≥10% fall FEV_1_ (3) | 58–96% | 65–78% | 202 (48) | 203 (48) | Moderate
Mannitol | 3, N=423 | Mannitol: ≥15% fall FEV_1_ (3) | | | | | Moderate

ECT = exercise challenge test; EVH = eucapnic voluntary hyperpnea; FEV_1_ = forced expiratory volume in 1 second; FRAST = free running asthma screening test; MCH = methacholine; PC = provocative concentration

Self-report. Since many patients present to clinicians with simply their story of breathing difficulties following exercise, the first question in this diagnostic review examined the accuracy of self-reported history or symptoms. EIB/EIA may be associated with symptoms such as shortness of breath, cough, wheeze and chest pain,18 and therefore these symptoms may lead clinicians to suspect EIB/EIA. For clinicians and patients, the diagnostic test characteristics of self-report are important to understand.

Despite extensive searching, only two studies addressed this question. While the results of one of the studies21 comparing post-exercise cough to an ECT are encouraging (89 percent sensitivity, 86 percent specificity), this is not sufficient evidence to conclude that self-report of symptoms is a reliable diagnostic tool for EIB/EIA (Table 41). There were too few studies to produce reliable ROC curves. Furthermore, given the complexity and variability of respiratory symptoms, recent research in chronic asthma has shown that objective lung testing is vital for a valid diagnosis165 and there is no reason not to apply this to a diagnosis of EIB/EIA.

Quality of evidence. The evidence from this group of two studies was graded as “very low”. Both study designs were rated low and there are serious limitations due to the lack of a representative spectrum of participants and uncertainty whether the ECTs met the ATS guideline recommendations.18 The diagnostic thresholds differed and the sensitivity estimates are inconsistent and imprecise.

Methacholine (MCH) challenge. MCH is considered a direct challenge as it acts on smooth muscle acetylcholine receptors, causing contraction and airway narrowing.23 It has been noted that airway responsiveness to pharmacologic agents such as MCH differs from hyper-responsiveness in response to physical stimuli such as exercise and osmotic agents.18

The review identified 16 studies that met the inclusion criteria for the diagnostic test accuracy review of the MCH challenge. Overall, the study quality varied, and there was a concern of spectrum bias in all but one study.23 Regardless of the threshold level for MCH (8 mg/ml or 16 mg/ml), there was considerable heterogeneity across individual study estimates for sensitivity (66 to 100 percent at 8 mg/ml; 0 to 100 percent at 16 mg/ml) and specificity 0 to 100 percent at either threshold. (Table 41) Moreover, the area under the curve (AUC) of the ROC was marginally more than 0.5 for any of the FEV_1_ cutpoints (10, 15, or 20 percent) or MCH thresholds. Based on these results we cannot conclude that the MCH challenge is a valid test to diagnose EIB/EIA.

Unlike exercise challenges, a positive airway response to MCH does not infer the presence of inflammatory cells or their mediators;20 therefore, it is not surprising that MCH shows variable sensitivity and specificity to detect EIB/EIA. It has been suggested18 that a positive MCH test should not be used to infer EIB/EIA and likewise, a negative MCH should not be used to exclude EIB/EIA.

Quality of evidence. The evidence from this group of 15 studies was graded as “moderate”. The study designs were rated high; however, there are serious limitations to the body of evidence as a whole. Only one study had a representative spectrum of participants and blinded the assessors to test results. It is unclear whether eight of the ECTs met the ATS guideline recommendations.18 The sensitivity estimates are reasonably consistent but are imprecise in the EIA participants. Specificity estimates are inconsistent and imprecise.

Sport or venue specific challenges. Sport or venue specific challenges refer to challenges in the specific sport (e.g., basketball, soccer) or at the venue of activity (e.g., hockey arena, swimming pool). They are advantageous in that the athlete can exercise in the conditions where they become symptomatic and the tests are reasonably inexpensive; however, coordinating the two tests and ensuring good quality control on both can be problematic.

Five studies addressed the key question of sport or venue specific exercise challenges (Table 41). Three studies focused on swim challenges and two assessed cold weather challenges. All studies involved elite athletes. The sensitivity of the field tests ranged from 0 to 100 percent. Specifity also ranged from 0 to 100 percent; however, in one study,41 all participants had a history of EIB/EIA and therefore had a high pre-test probability of testing positive on both tests. In the studies that did not have this select population, the specificity ranged from 79 to 100 percent. There were too few studies to produce reliable ROC curves. Althought sport specific challenges are one of the recommended challenges for diagnosing EIB/EIA in elite athletes,34 in total, only seven athletes tested positive in their own field of competition while 16 were positive on a standardized ECT. It is not clear why this occurred, although it is possible that the level of minute ventilation and differences in environmental conditions played a role. Sport specific challenges may be useful in identifying athletes who do not have EIB/EIA but additional testing such as a standardized ECT may be required to confirm a diagnosis.

Quality of evidence. The evidence from this group of five studies was graded as “low”. The study designs were rated high; however, there are serious limitations to the body of evidence as a whole. No study had a representative spectrum of participants or blinded the assessors to test results. It is unclear whether two of the ECTs met the ATS guideline recommendations.18 Both the sensitivity and specificity estimates are inconsistent and imprecise.

Eucapnic voluntary hyperpnea (EVH) challenge. EVH challenge is a test based on the premise that the increased minute ventilation with exercise is responsible for airway constriction in susceptible participants.19 Currently, EVH is the challenge recommended by the International Olympic Committee Medical Commission to identify EIB/EIA among Olympic athletes.48

The stimulus for the airways to narrow in response to exercise is the water lost by evaporation from the airway surface and the osmotic and thermal effects arising from this.18 Theoretically, conditioning large volumes of cold inspired air places a greater burden on the airways to reheat and rehumidify it quickly as compared with inspiring warmer, humid air. Therefore, it is likely that additional (i.e., small) airways would be recruited to achieve the task and this would increase airway dehydration. Similarly, inspiration of cold air during EVH would increase the likelihood of bronchoconstriction compared with EVH using room temperature air. In the study by Eliasson et al.42 participants performed EVH tests while inspiring air at room temperature or inspiring air cooled to between minus 18°C and minus 26°C. Despite the increased conditioning of the air required during the cold air trial, there was no difference in post-EVH FEV_1_ response between the cold versus room temperature challenges.

It is worth noting that EVH challenges are likely the most technically difficult of all the EIB/EIA diagnostic tests to perform for a variety of reasons. First, minute ventilation must be measured accurately in real-time and displayed so that participants can receive feedback on their target minute ventilation. The substantial increase in minute ventilation with the challenge will cause hypocapnea, which can cause bronchoconstriction166 as well as nausea and fainting. It is for this reason that EVH trials are performed with participants rebreathing a gas mixture of approximately five percent CO_2_ so that arterial CO_2_ levels can be maintained at resting eupneic levels. Importantly, rebreathing a gas mixture for 5 to 6 minutes may also cause hypoxemia if the gas mixture does not contain an elevated oxygen concentration. Thus, additional monitoring equipment as well as well-trained respiratory or exercise physiology staff are required to maintain CO_2_ and O_2_ levels within normal physiological ranges during EVH challenges.

Seven studies met the inclusion criteria to assess the diagnostic accuracy of EVH (Table 41). In general study quality raised questions of bias, in particular, there was a concern of spectrum bias in all studies. Overall, the sensitivity and specificity was heterogeneous with values ranging 25 to 100 percent, and 0 to 74 percent, respectively. It is unclear whether an EVH challenge is identifying the same people that experience a fall in FEV_1_ of 10 percent or more on an ECT, particularly in a population of athletes with an unclear history of asthma. The EVH challenge resulted in a higher proportion of false positives (FP) (i.e., negative on the ECT but positive on EVH) among participants with no or unknown history of EIB/EIA. The proportion of FP ranged from 25 to 71 percent. The participants included both elite athletes (n=63) and those with unknown activity levels (n=20). Based on the available evidence, it is unclear if the EVH challenge is more sensitive to EIB/EIA, or if the mechanism that triggers the bronchoconstriction is different from that for the ECT, or if level of minute ventilation achieved on an ECT according to ATS recommendations is less than the level achieved in an EVH challenge particularly in athletes. Among participants with a history of EIB/EIA, the proportion of FPs ranged from 0 to 5 percent in participants with unknown activity levels. Among athletes, the proportion with a FP result was 27 percent. Further research is needed to determine if the EVH challenge would be an appropriate add-on test to a standardized ECT in athletes with symptoms of EIB/EIA. Based on this evidence, it is unclear whether EVH challenge is more accurate diagnostic test for EIB/EIA compared with a standardized ECT.

Quality of evidence. The evidence from this group of seven studies was graded as “low”. The study designs were rated high; however, there are serious limitations to the body of evidence as a whole. No study had a representative spectrum of participants or blinded the assessors to test results. It is unclear whether the ECTs met the ATS guideline recommendations.18 Furthermore, the sensitivity and specificity estimates are inconsistent and imprecise.

Free running asthma screening test (FRAST). Free running has often been used in screening large groups for EIB/EIA because of the ease in performing such challenges.19 Three studies met the inclusion criteria for assessing the diagnostic accuracy of the FRAST (Table 41). Participants in all the studies were children (younger than 15 years), and all tests took place indoors. Despite being able to run freely during the FRAST, the reported average heart rate during the challenge for each group was 80 percent or greater of maximum and was comparable to the ECT. None of the studies had a representative patient spectrum. Sensitivity and specificity were modest (60 to 67 percent and 47 to 67 percent, respectively). There were too few studies to produce reliable ROC curves. While the FRAST is easy to perform, there is insufficient evidence to conclude that it accurately identifies people with EIB/EIA compared to a standardized ECT.

Quality of evidence. The evidence from this group of three studies was graded as “very low”. The study designs were rated medium; however, there are serious limitations to the body of evidence as a whole. No study had a representative spectrum of participants or blinded the assessors to test results. It is unclear whether two of the ECTs met the ATS guideline recommendations.18 The sensitivity and specificity estimates are consistent but imprecise.

Mannitol provocation test. Recently, a mannitol provocation test has been developed to examine airway hyper-responsiveness. Like exercise, mannitol is considered an indirect bronchial provocation test. Mannitol increases osmolarity, which causes the release of endogenous mediators such as prostaglandin, leukotrienes and histamine, and results in smooth muscle contraction.50,51 Mannitol has the advantage that it can be performed with minimal equipment (i.e., a metered-dose inhaler and spirometer).

Three studies met the inclusion criteria for the diagnostic test accuracy review of mannitol (Table 41). Sensitivity ranged from 58 to 96 percent; specificity ranged 65 to 78 percent. At this time there is insufficient evidence to conclude that the mannitol provocation test is a reliable test to diagnose EIB/EIA.

Quality of evidence. The evidence from this group of 3 studies was graded as “moderate”. The study designs were rated high; however, there is reasonable concern regarding the limitations to the body of evidence as a whole. Only one study had a representative spectrum of participants and blinded the assessors to test results. All three of the ECTs met the ATS guideline recommendations.18 The sensitivity and specificity estimates are reasonably consistent but are imprecise.

### Limitations

In addition to the issues identified regarding ECT and index test performance, there are several limitations that need to be discussed regarding systematic reviews of diagnostic test accuracy. First, there is a possibility of publication bias. The impact of publication bias on the results of diagnostic test accuracy reviews is not well understood nor have the tools to investigate publication bias in these reviews been developed.167 However, we conducted a comprehensive and systematic search of the published literature for potentially relevant studies. Search strategies included combinations of subject headings and free text words. These searches were supplemented by handsearching for gray literature (i.e., unpublished or difficult to find studies). Despite these efforts, we recognize that we may have missed some studies.

Overall, EIB/EIA literature is not indexed well and authors are not consistent in using the terms in titles or abstracts that clearly describe the scope of their research. There are also a variety of activities and sports that can potentially cause EIB/EIA. It is impossible to account for every variation and term within the search strategy. Knowing this, the search strategy was designed to be highly sensitive in order to avoid missing any potentially relevant articles and 18 electronic databases were searched in order to retrieve as many pertinent studies as possible.

There is also a possibility of study selection bias. We employed at least two independent reviewers to identify potentially relevant studies, and feel confident that the studies that were excluded from this report were done so for consistent and appropriate reasons.

A further limitation was that not all studies that seemed potentially relevant were designed as diagnostic test accuracy studies but they did compare two test methods of interest; however, the data presented were not in a useful form to evaluate the diagnostic accuracy of the comparison. In order to be included, a study had to report sufficient data to generate a 2x2 table of the reference standard and index test results based on one or more diagnostic thresholds.

Finally, we did not pool the sensitivity and specificity data in this report. A decision was made that the populations, tests, and study designs were sufficiently heterogeneous for each of the key questions that pooling would be invalid. Where appropriate we wanted to produce AUC results for ROC curves; however, given the small number of studies that addressed each of the key questions, an ROC curve was possible only for MCH versus ECT.

### Conclusions

Despite exhaustive efforts to identify evidence regarding the diagnostic test characteristics of tests used to identify patients with EIB/EIA, few studies were identified. Moreover, the studies that were identified suffered from considerable test variability and spectrum bias. In all included studies, the participants were volunteers and varied from exclusively elite athletes with or without documented or suspected EIB/EIA to patients with or without documented or suspected EIB/EIA who were not trained athletes. In the many of studies physical fitness was not addressed at all. The diversity in included populations and the fact that there were not many studies comparing the same diagnostic tests precluded more detailed subgroup analysis of the issue of EIB versus EIA. However, we do not believe these limitations invalidate the results presented in the review as the reviewers analyzed the data as vigorously as it allowed. The results of this report apply to patients being screened for EIB/EIA as well as the clinicians caring for them.

On the basis of this review, there is no clear evidence to support that any of the six index tests studied are equivalent to, or better than, the standardized ECT to diagnose EIB/EIA. At this time none can be recommended to replace the ECT for diagnosing EIB/EIA in the general population. EIB/EIA remains a complex phenomenon that does not always occur in the same individual every time they under go a challenge. Combining history, symptoms, objective testing plus trial and error therapy may still be the preferred path to an active life in those that have EIB/EIA.

## Therapy Review

Using a comprehensive search strategy and concerted efforts to avoid publication and selection bias, this review identified all the available evidence to assess the effectiveness of six interventions (five pharmacologic and one nonpharmacologic) to treat EIB/EIA. Overall, we identified 109 studies that met our inclusion criteria. The number of studies available to address each of the six key questions ranged from 4 to 17 involving between 40 and 272 participants.

There are many methodological considerations when undertaking a systematic review of the therapeutic literature. When determining the effectiveness of a therapy, the highest level of evidence arises from well-conducted RCTs. EIB/EIA is a unique condition. It would not exist if not triggered by vigorous exercise and, although the bronchoconstriction can be severe; it generally resolves spontaneously over the course of an hour and leaves no permanent sequelae. The therapeutic drugs used for EIB/EIA are short-acting and are rapidly cleared from the body. As a result, therapy trials for this condition lend themselves to crossover RCT methodology and the majority of trials in these reviews employed this design. The advantage of a crossover compared with a parallel group design is that all participants receive all interventions and, therefore serve as their own control. This reduces sample size requirements. However, concerns with washout periods, carryover effects, and changes over time mean trialists must design the timing and frequency of ECTs with this in mind.

Since asthma is a common chronic condition, in most countries guidelines exist for the treatment of this disease. Not surprisingly, the treatment options for EIB/EIA mirror those for symptoms in chronic asthma—mainly, bronchodilators and anti-inflammatory agents. Like an asthma attack, an EIB/EIA attack can produce symptoms such as shortness of breath, cough, wheeze and chest pain,143 and, as in asthma, these symptoms are amenable to treatment with bronchodilators. Since many of the anti-inflammatory agents improve asthma control, clinicians and researchers have been curious to know if they also have an effect on EIB/EIA.

The following sections summarize the pharmacologic and nonpharmacologic treatments addressed in this report (Table 42 and Figure 28). The pharmacologic interventions are further divided into bronchodilating and anti-inflammatory agents.

Figure 28 Mean difference in the maximum percent decrease in FEV_1_ following ECT with prophylactic therapy relative to placebo

NOTE: The reduction in FEV_1_ post-exercise challenge with prophylactic therapy was compared with FEV_1_ post-exercise challenge with placebo (i.e. placebo response - prophylactic response), and therefore negative values favor the prophylactic pre-treatment.

Table 42 Prophylactic therapy for EIA: Pulmonary function results

Comparisons Intervention vs. control | N trials (SS_i_ vs. SS _c_) MD % fall FEV_1_/PEF (95% CI)^*^ | Clinical protection 50% N trials (SS_i_ vs. SS _c_) RR (95% CI) † | Mean % protection of intervention over control (95% CI) | Complete protection N trials (SS_i_ vs. SS _c_) RR (95% CI) † | Evidence Grade
Leukotriene receptor antagonists vs. placebo | N=9 (267 vs.267) 8.9 (6.9, 11.0) | NR | NR | ≤10% fall FEV_1_ N=4 (124 vs. 123) 1.87 (0.77, 4.56) | Moderate
Inhaled corticosteroids vs. placebo | N=4 (50 vs. 50) 5.0 0.0, 9.9) | NR | BV 6%; BUD 17%; FP 49% | NR | Moderate
MCS (Nedocromil sodium) vs. placebo | N=17 (240 vs. 240) 15.6 (13.2, 18.2) | NR | 51 (46, 55) | NR | Moderate
Nedocromil sodium vs. Sodium cromoglycate | N=7 (97 vs. 97) 0.9 (−2.7, 4.5) | N=6 (78 vs. 78) 1.12 (0.89, 1.40) | NR | ≤10% fall FEV_1_ N=6 (78 vs. 78) 1.0 (0.7, 1.4) | Moderate
MCS vs. Anticholinergics | N=8 (183 vs. 175) 6.7 (3.3, 10.0) | N=5 (56 vs. 48) 1.35 (1.00, 1.83) | 11.2 (2.4, 20.0) | ≤15% fall FEV_1_ N=8 (177 vs. 169) 1.3 (1.1, 1.6) | Moderate
SABA vs. MCS | N=12 (271 vs. 272) 6.8 (4.5, 9.2) | N=6 (77 vs. 77) 1.4 (1.1, 1.7) | 22.7 (11.9, 33.4) | ≤15% fall FEV_1_ N=9 (225 vs. 226) 1.4 (1.2, 1.8) | Moderate
SABA + MCS vs. SABA | N=5 (40 vs. 40) 1.3 (−6.3, 8.9) | N=3 (37 vs. 37) 0.9 (0.7, 1.1) | 10.3 (−27.0, 6.5) | ≤15% fall FEV_1_ N=4 (44 vs. 44) 0.9 (0.5, 1.4) | Moderate
LABA vs. Placebo | N=4 (55 vs. 55) 25.1 (18.0, 32.3) | NR | 86% | NR | Moderate
Anticholinergics (Ipratropium bromide) vs. placebo | N=11 (142 vs. 142) 9.8 (5.0, 19.5) | N=6 % achieved=60 (48, 72) | NR | ≤10% fall FEV_1_ N=7 (74 vs. 74) 4.5 (1.2, 10.9) | Moderate
Interval warmup vs. no warmup | N=4 (56 vs. 56) 10.6 (6.5, 14.7) | NR | NR | ≤15% fall FEV_1_ N=1 1/12 (8.3%) | Low
Continuous low intensity warmup vs. no warmup | N=3 (37 vs. 37) 12.6 (−1.5, 26.7) | NR | NR | ≤15% fall FEV_1_ N=1 6/12 (50%) | Low
Continuous high intensity warmup vs. no warmup | N=2 (13 vs. 13) 9.8 (−6.4, 26.0) | NR | NR | NR | Low

BUD = budesonide; BV =Betamethasone valerate; FEV1 = forced expiratory flow in 1 second; FP=fluticasone ICS = Inhaled corticosteroid; LTRA = leukotriene receptor antagonist; MCS = mast cell stabilizers; MD = mean difference; NR = not reported; PEF = peak expiratory flow; RR = risk ratio; SABA = short-acting beta-agonist; SSi = sample size intervention; SSc = sample size comparison

* a positive MD indicates intervention is better;

† RR>1 indicates intervention is better.

## Pharmacologic Interventions

### Bronchodilating Agents

SABA/LABA. Beta_2_-receptors on the airway smooth muscle are responsible for bronchodilation; beta_2_-agonist agents attach to these receptors and are effective bronchodilators. SABA agents have been the mainstay of EIB/EIA prevention and treatment for many years. With the development and availability of LABA agents, more research has been applied to their effectiveness in EIB/EIA.

Although the evaluation of SABA or LABA versus placebo for prophylactic EIB/EIA use was not the focus of this review, results were available in some comparisons on which to base a reasonable conclusion. In the mast cell stabilizer (MCS) review78 SABA agents were approximately 7.0 percent more effective than MCS. Using data from the SABA groups in the 12 studies in the comparison with MCS,78 SABA reduced the maximum percent fall in FEV_1_ to an average of 4.3 percent (SD±14.1; range 1.0 to 15.5) whereas as the MCS groups averaged a maximum percent fall in FEV_1_ of 11.0 percent (SD±17.7; range 4.2 to 27.2).78 The day 1 data for the four LABA groups in the tachyphylaxis review showed that LABA reduced the fall in FEV_1_ to an average of 3.7 percent (SD±8.7). This indicates that LABA is also an effective agent for attenuating the bronchoconstriction that is characteristic of EIB/EIA (Figure 28).

While SABA and LABA treatments are effective, caution is advised. The data from this review support that a degree of tachyphylaxis is associated with the regular use of both beta-agonist agents. The pooled results from four LABA trials demonstrated the maximum percent fall in FEV_1_ following an ECT after 4 weeks of regular LABA use was of a greater magnitude in the LABA arm than the placebo arm. Similar results were shown in the two studies that investigated SABA after only 1 week of regular use. While the results were statistically significant, there was no discussion on whether this was clinically significant or important to the participants. These data do not imply that SABA or LABA agents lose their effectiveness altogether following regular use; however, the magnitude of their effectiveness is reduced. There are no data on whether the tolerance to these agents continues to increase as duration of regular use increases to several months.

Short-acting anticholinergic (SAAC) agents. Anticholinergic agents are used in respiratory conditions to decrease mucus production and as weak bronchodilators. The original SAAC agent used in asthma was atropine; however, ipratropium bromide (IB; Atrovent™) and oxitropium bromide (OB; Oxivent™) are more commonly used. Long-acting anticholinergics such as tiotropium (Spiriva^®^) are available; however, they are more commonly used in the management of chronic obstructive pulmonary disease. SAAC agents are an intuitive addition to the treatment regimen given the concerns regarding the potential for tachyphylaxis with regular use of SABA and LABA agents.

We identified 18 trials (211 patients enrolled) that compared SAAC agents with placebo in single-dose prophylactic treatment of EIB/EIA. Twelve of the 18 researched IB and, given the worldwide availability and use of this drug, the discussion focuses on this agent.

The pooled results demonstrated a consistent benefit attributable to IB (Table 42 and Figure 28). The maximum percent fall in FEV_1_ at an ECT less than 2 hours following treatment was reduced by approximately 12 percent (17 percent in PEF) compared with placebo. These clinically relevant results, however, are tempered by the presence of moderate heterogeneity. Complete protection was achieved 4.5 times more often with IB than placebo. This conclusion is strengthened by the negligible heterogeneity (I2=0 percent). Only four of 18 studies reported side effects; there were no differences identified between IB and placebo. Despite the theoretical autonomic nervous system risks associated with use of SAAC agents (e.g., dry mouth, glaucoma, confusion), there is sufficient evidence from the acute respiratory literature to suggest that a single dose of IB is safe in patients with EIA.168,169

From the available evidence, it appears that when used as a pre-exercise treatment IB can be effective and safe for patients with EIB/EIA. The strength of the body of evidence is moderate.

### Anti-inflammatory Agents

Mast cell stabilizers (MCS). Mast cells are important cellular contributors to the inflammatory cascade seen in asthma. MCS are asthma agents that stabilize the mast cell and prevent the release of inflammatory mediators. They are used as weak anti-inflammatory agents in mild to moderate chronic asthma. We identified three existing Cochrane reviews that addressed MCS as prophylactic treatment for EIA (Table 42 and Figure 28). The first review76 included 21 trials that studied a single prophylactic dose of nedocromil sodium (NCS) in doses ranging from 1 mg to 8 mg, compared with a placebo. The second review77 (9 trials) compared the effects of a single prophylactic dose of NCS, in doses ranging from 2 mg to 8 mg, to one of sodium cromoglycate (SCG), in doses ranging from 10 mg to 20 mg. The summary data from this review failed to identify differences with respect to the maximum percent decrease in FEV_1_, complete protection, or the degree of clinical protection between the two drugs. Given this result, the third review78 included trials that compared either NCS or SCG (collectively called MCS) to an anticholinergic agent (n=11), a SABA alone (n=20), or a combination of a SABA and MCS (n=10).

All studies in these three reviews included RCTs conducted on children (6 to 17 years) and adults (18 years and older) with stable asthma who experienced EIA. The majority of studies employed a crossover design with adequate time between ECTs to eliminate carryover effects but avoid period effects.

In people with stable asthma that experience EIA, NCS taken 15 to 60 minutes prior to exercise significantly reduced the severity of EIA in both children and adults. Regardless of dose, timing, delivery method, or age, NCS provided a clinically significant benefit that was 51 percent greater than placebo. The average post-exercise percent fall in FEV_1_ across the 16 studies after NCS was 15.6 percent (range 10 to 29.8) compared with a fall of 30.2 (range 20.8 to 48.1) on placebo (MD=15.6 percent; 95 percent CI: 13.2, 18.1). There was substantial heterogeneity in this result that was eliminated when subgroups based on severity of EIA were compared. The benefit from NCS was more pronounced in those with severe EIA (fall in FEV_1_ of 30 percent or greater).

When either NCS or SCG was compared to anticholinergics the data indicated MCS agents were somewhat more effective than anticholinergics but not as effective as SABA agents. The combination of SABA and MCS agents did not provide significant advantages over a SABA alone. Data on the safety of these agents were not routinely reported, but when it was, no serious side effects were observed. The strength of the body of evidence is moderate.

Inhaled corticosteroids (ICS). The main anti-inflammatory agents used for chronic and acute asthma management are ICS, either alone or in combination with LABA agents. ICS agents are used in respiratory conditions to decrease inflammation and reduce mucus production; they have no direct bronchodilating effects. Contrary to systemic corticosteroids, ICS are inhaled and exert their effects locally; little of the available drug is absorbed into the systemic circulation. There are a large number of ICS agents available on the North American market (in alphabetical order): beclomethasone (QVAR™), budesonide (Pulmicort™), flunisolide (Aerobid™), fluticasone (Flovent™), and triamcinolone (Azmacort™). Agents also exist that combine ICS with LABA in one inhaler (in alphabetical order): budesonide and formoterol (Symbicort™) and fluticasone and salmeterol (Advair™). Koh et al.107 published a systematic review involving six studies comparing 4 to 12 weeks of daily ICS use with placebo for prevention of EIB/EIA. The reviewers concluded that 4 or more weeks of daily ICS use attenuated the fall in FEV_1_ in ranges of 7 to 14 percent over placebo. There was not enough data at that time to assess ICS used as a single-dose prophylactic for EIB/EIA. We identified four trials involving 50 children and adults that did so. Though the methodological quality of the studies was moderately good, questions remain on how adequately they were randomized and double blinded.

Although the pooled results presented here favor ICS, they failed to demonstrate a statistically or clinically beneficial reduction in the maximum percent fall in FEV_1_ or PEF compared with placebo (Table 42 and Figure 28). No sound conclusions could be drawn on the complete or clinical protection provided by ICS either. None of the studies reported adverse effects. Despite the theoretical risks associated with ICS use, there is sufficient evidence from the acute respiratory literature to suggest that a single dose of ICS is safe in patients with EIB/EIA. Adverse effects such as cataracts,170 adrenal suppression, osteoporosis and fractures,171 occur with long-term use; they are not likely an issue of concern with episodic use.

From the available evidence we cannot conclude that pre-treatment with ICS agents is an effective and safe strategy for patients with EIB/EIA. The strength of the body of evidence is moderate.

Leukotriene receptor antagonists (LTRA). Leukotrienes are produced by the cysteinyl leukotriene pathway and are implicated in both bronchoconstriction and in the inflammatory cascade leading to worsening asthma. LTRAs, which block this pathway, are available for the management of chronic and acute asthma.

We identified nine trials involving 535 patients and 10 comparisons of prophylactic treatment of EIA with LTRA compared with placebo. The methodological quality of the studies was reasonably strong. The pooled results demonstrated a consistent though modest benefit in favor of LTRAs. LTRAs were superior to placebo and reduced (i.e., improved) the percent fall in FEV_1_ at the earliest measurement (usually less than 2 hours) by approximately 9 percent compared with placebo (Table 42 and Figure 28). The protective effect of this pre-treatment extended up to the 8 and 24 hour measurements of FEV_1_ when there was a 7 and 5 percent improvement over placebo, respectively. It is likely that the weak anti-inflammatory effect of LTRAs is responsible for this extended action. These results are tempered by the presence of moderate heterogeneity (50 to 70 percent) in all meta-analyses. Few studies reported side effects and the data that were reported identified no differences between LTRAs and placebo; however, there is sufficient evidence from the chronic asthma literature to suggest that LTRAs are safe.172

From the available evidence, it appears that LTRAs can be somewhat useful and safe as pre-exercise treatment for patients with EIB/EIA. The strength of the body of evidence is moderate.

### Nonpharmacologic Interventions

As an alternative to drug interventions to attenuate and/or prevent EIB/EIA, many athletes, trainers and researchers advocate specific warmup exercises as a method to achieve similar results. We identified seven trials involving 128 patients that compared various forms of warmup activities to no warmup in the pre-exercise treatment of EIB/EIA. Convincing conclusions cannot be made regarding warmups because results are tempered by the methodologically poor quality of the studies and the variability in the warmup protocols studied.

Three general approaches were examined: interval, continuous high intensity (two standardized exercise challenges 45 minutes apart), and continuous low intensity (treadmill runs at work rates of 60 percent). The pooled results varied (Table 42 and Figure 28). Compared with no warmup, interval warmups attenuated the fall in FEV_1_ following a subsequent ECT by a statistically significant 11 percent. For both high and low intensity continuous warmups, there was a 10 to 12 percent improvement in FEV_1_ but it was not statistically significant and it was associated with substantial heterogeneity. Combinations of various warmup protocols within studies also demonstrated protection against EIB/EIA with an attenuating factor between 10 and 11 percent. Eck et al.98 reported that 79 percent of participants achieved protection (but did not designate a cutpoint for this) when a combination of warmup activities was used as a pre-treatment for EIB/EIA. Pooling the study data was not possible due to the heterogeneity of the warmup protocols.

From this evidence, it appears that certain warmup protocols are effective at reducing the degree of airway obstruction associated with EIB/EIA. Combination warmups show promise; however, it is unclear whether continuous warmups are effective in this condition. The strength of the body of evidence is low.

### Limitations

In addition to the methodological issues identified previously regarding trial designs in EIB/EIA, there are several limitations that need to be discussed regarding systematic reviews. First, there is a possibility of publication bias in this systematic review. By missing unpublished and/or negative therapy studies, we may be overestimating the therapeutic benefits of certain interventions. A comprehensive and systematic search of the published literature for potentially relevant studies was conducted to avoid publication bias. This was supplemented by searching for gray literature (i.e., unpublished or difficult to find studies. Despite these efforts, we recognize that we may have missed some of these types of studies.

There is also a possibility of study selection bias. However, we employed at least two independent reviewers and feel confident that the studies that were excluded from this report were done so for consistent and appropriate reasons. Our search was comprehensive, so it is unlikely that there are many studies in press or publication that were missed.

There are several other issues with respect to populations, interventions, outcome assessments, and controls that require discussion.

Population. In general the populations involved in the therapy trials were volunteer recruits from hospital and outpatient clinics or schools for asthmatic children. All had confirmed asthma and documented EIA. The lack of reporting certain baseline data precluded more detailed subgroup analysis that would be of interest to the medical community. Larger sample sizes would help to provide more conclusive results. Overall, we do not believe these limitations invalidate the results presented in the therapy review as the reviewers analyzed the data as vigorously as was possible.

Intervention. Despite the variation in dose, delivery method, and timing of prophylactic drug treatment, these studies employed RCT methodology and standardized the drug interventions that were investigated. The major limitations are the small sample sizes and small number of trials that investigated each drug category. The interventions investigating warmup protocols were not standardized across trials. While we divided the warmup interventions into three groups based on the level of intensity required, each warmup approach varied considerably from study to study. Overall, we do not believe these limitations invalidate the results presented in the review; however, they do limit robust interpretation, drawing firm conclusions, and generalization of results.

Control. Many of the patients in the pharmacologic studies were administered placebo agents as the control treatment. These agents were often similar in appearance or delivery; however, it may have been possible for patients to detect differences among treatments, especially the bronchodilators such as SABA, LABA and SAAC agents. Also, the studies used a range of placebo devices and propellants, some of which provided significant protection to a large proportion of participants in the study. It was not possible to blind the participants to the warmup protocols in the refractory studies and it was not reported if the purpose of the intervention was known to them. Furthermore, blinding of the person conducting and assessing spirometry following the intervention and the ECT was rarely reported. It is impossible to determine how this might have affected the results. None of the included studies reported the patient’s perception of treatment received. Overall, we do not believe these limitations invalidate the results presented in the review; however, they do raise questions surrounding the lack of blinding and how that may affect estimates of the overall treatment effect.13

Outcome. The pulmonary function outcomes reported were not standardized and comprised various forms of FEV_1_ and PEF measures. Some could not be transformed or calculated from individual patient data and therefore were not included in a pooled analyses. Also, the maximum percent fall in FEV_1_ cutpoints to confirm EIB/EIA ranged from a fall of 10 to 20 percent. The ATS convention is to accept a 10 percent fall in FEV_1_, and that was what was employed in the majority of studies.

Outcome reporting always included a pulmonary function measure following the intervention and ECT. However, reporting other useful outcomes such as clinical and complete protection data was not consistent (Table 42). Wherever possible, we calculated these results from IPD. Few secondary outcomes were reported. For example, patient preference for the intervention, effect on performance, effect on signs and symptoms were absent. Side effect profiles were also poorly reported; however, sufficient evidence exists for the safety of many of these agents from the chronic asthma literature. Overall, we do not believe these limitations invalidate the results of the therapy review.

Finally, the comparative effectiveness of these treatments is difficult to determine. There are few direct comparisons among specific interventions for EIB/EIA treatments and this makes decisionmaking for patients and clinicians problematic. The indirect comparisons provided in Figure 28 are to be used with caution.

### Conclusions

Despite exhaustive efforts to identify evidence regarding therapeutic effectiveness of various interventions used to treat people with EIB/EIA, only a small number of studies met the inclusion criteria for each key question. All of the studies recruited people with asthma and reproducible EIA. Evaluation of therapeutic effect on EIB was not possible. Many of the studies suffered from potential biases. Nonetheless, this summary represents the most comprehensive review of therapies for EIA published to date.

On the basis of this review, we can conclude that all bronchodilators that were examined are effective at attenuating and even preventing the FEV_1_ drop associated with EIA (Figure 28). There is emerging evidence of the development of tachyphylaxis associated with daily use of SABA and LABA agents. This suggests that SABA and LABA agents should be used only “as required,” rather than regularly, in order to preserve their use as prophylactic agents for EIA. SAAC agents were found to be effective pre-EIA bronchodilator agents.

We can conclude that the anti-inflammatory agents examined provide mixed results. For example, MCS agents are very effective in attenuating or eliminating the FEV_1_ drop associated with EIA. There is some role for LTRA in the treatment of EIA; however, the attenuation of EIA appears less than with other anti-inflammatory agents. There is limited evidence of a benefit associated with pre-treatment with ICS compounds. The long-term benefit of ICS agents in asthma is no longer questioned,107 and it is possible that better control of chronic airway inflammation may benefit patients with EIA specifically.

Finally, pre-exercise interval warmup appears to be useful in significantly attenuating or eliminating the FEV_1_ falls associated with EIA. This set of interventions requires further research on the relative effectiveness of various types of warmup.

## Recommendations for Future Research

Efforts are needed to improve the overall quality of reporting of primary studies of diagnostic test accuracy. The STARD checklist105 details 25 items that address the level of detail that should be specified within such studies including descriptions of participants, tests methods, statistical methods, and results. This could be considered as a guide for authors reporting studies that evaluate diagnostic tests and for journals that publish EIB/EIA-related research.

Studies designed to more carefully examine the methodology of the standard ATS ECT test are needed. Specifically, guidelines state that the inspired air temperature must be less than 25^o^C, and less than 50 percent relative humidity. Studies have used inspired air as cold as −18^o^C and many have used medical compressed air, which has a relative humidity of 0 percent as the air leaves the tank. Colder, drier air would result in the greatest increase in osmolarity of the airway surface and thus most likely cause EIB/EIA. Additional studies are needed to more thoroughly examine how inspired air affects EIB/EIA so that a more standardized ECT guideline can be developed.

Future purposely designed studies to compare the diagnostic characteristics of different diagnostic methods are needed. New tests such as mannitol are encouraging; however, currently there are insufficient data to allow for a strong recommendation of this test. Particular attention in future studies must be given to including a representative sample of participants with suspected EIB/EIA. Studies that prospectively recruit participants and blind the reference standard results to those who interpret the index test results are needed.

To determine if the response to diagnostic tests differs in those with EIB versus EIA, those with atopy or no atopy, or other potentially defining characteristics, appropriate populations need to be included, adequate baseline data reported, and comparative analyses by the characteristics of interest performed and reported.

With regard to the systematic review of therapy for EIA, there are several issues with respect to methodological quality, populations, interventions, outcome assessments, and controls that require discussion.

Efforts are needed to improve the quality of reporting primary studies (i.e., randomized controlled trials). The CONSORT Statement106 could be considered as a guide for authors reporting trials and journals that publish EIB/EIA-related research. Most trials in this review used a crossover design. Concerns regarding crossover trials center on three factors: drug carryover effects, period effects, and statistical issues. Data should be reported in a manner that allows analyses to confirm the presence or absence of a carryover effect. Future studies should focus on complete reporting of results by period and sequence to assure readers that these concerns have been accounted for.

Population: The populations involved in the therapy trials all had stable asthma and confirmed EIA. Athletic status was not reported. This finding, coupled with the small number of studies investigating some interventions, precluded more detailed subgroup analysis of the issue of EIB/EIA in elite athletes. Additional investigations of treatment effects in patient subgroups defined by asthma severity, age, and activity level are clearly indicated.

More trials in clinically homogenous groups of patients with EIB and patients with EIA are needed to better explore and characterize differences in the efficacy of interventions between these two conditions.

Intervention: The nonpharmacologic interventions were not standardized. Although the warmup interventions were divided into similar groups, each warmup approach varied from the others. Future research exploring different standardized warmup approaches is clearly indicated.

Control: Many of the patients in the pharmacological studies were administered placebo agents as the control treatment. These agents were often similar in appearance or delivered in similar appearing devices (inhaler agents) to the active treatment; however, it may have been possible for patients to detect differences among treatments, especially the bronchodilators such as SABA, LABA and SAAC agents. It is impossible to determine how frequently this occurred since most studies did not report the patient’s perception of treatment received. In addition, it was not possible to blind the participants to the warmup programs in the refractory studies. When the participant cannot be blinded, it is particularly important that the outcome assessor be blinded to all information that could bias the outcome measure or assessment (e.g., other test results, intervention given, challenge performed).

Outcome: The pulmonary function outcomes reported varied and studies used different diagnostic cutpoints ranging from a fall index of 10 to 20 percent. The ATS convention is to accept a 10 percent maximum fall in FEV_1._ While outcome reporting included detailed pulmonary function measures, the format was not standardized. Data on the proportion obtaining clinical and complete protection were often missing (Table 2).

Side effect profiles were also poorly reported. While there is evidence for the safety of many of these agents from the chronic asthma literature, it would be prudent for future research to capture adverse effects in the EIB/EIA population. Future trials of interventions to prevent or attenuate EIB/EIA should include clinically relevant secondary outcomes such as patient preferences, symptom scores, and sport performance effects (e.g., changes in athletic performance or endurance). More robust outcome reporting would further inform decision-making by athletes, physicians, and sporting bodies.