# Introduction

## What is Exercise-induced Bronchoconstriction and Asthma?

Vigorous physical exercise can be followed by transient clinical signs and symptoms of asthma due to airway narrowing. The phenomenon was first recorded around 150 AD by Aretaeus of Cappodocia.108 Airway obstruction following exercise was first observed among individuals with underlying asthma from which the term exercise-induced asthma (EIA) was derived. Asthma is a chronic inflammatory disorder of the airways in which many cells and cellular elements play a role, and it is associated with bronchial (or airway) hyper‐responsiveness.109 Similar post-exercise asthma-like symptoms have been observed in persons without the presence of co-existing asthma, particularly in athletes. In this population the phenomenon has been referred to as exercise-induced bronchoconstriction (EIB).1 In this report we define EIB as “the airway obstruction that occurs in association with exercise without regard to the presence of chronic asthma.” We define EIA as “the condition in which exercise induces symptoms of asthma in patients who have asthma.”1 (The two conditions will be discussed separately when the populations are specifically identified; otherwise, for the sake of brevity, they are collectively referred to as EIB/EIA.

The underlying mechanisms of EIB and EIA are multifactorial and complex. Whether the two phenomena have the same pathogenesis is still unknown and continues to be explored.110,111 In the early 1970s, Chan-Yeung et al.112 recognized that the severity of the airway constriction was associated with the level of ventilation. In normal nasal breathing, inspired air is heated to body temperature and is completely saturated with water in the first few generations of the airways. There is a marked increase in minute ventilation during and following strenuous exercise and, as a result, the nose is unable to condition the increased volume of air. The added burden on the lower airways, down to the tenth generation and beyond, to warm and humidify the large volume of air triggers osmotic and thermal changes.20,113,114 Loss of water in the periciliary fluid layer of the airway produces a hyperosmotic environment that may stimulate degranulation of pulmonary mucosa mast cells with subsequent release of several inflammatory mediators such as histamine, leukotrienes, prostaglandin, platelet activating factors, and neuropeptides from sensory nerves.115 Theorists propose that the released mediators stimulate bronchial smooth muscle spasm116 and rapid rewarming leads to increased bronchial circulation and engorged capillary beds (or airway edema) that may intensify the obstruction.114,117,118

The hallmark of EIB/EIA is that the acute airflow obstruction (measured by the forced expiratory volume in 1 second [FEV_1_]) peaks rapidly 3 to 15 minutes after exercise stops and then remits spontaneously within 20 to 60 minutes.2 It does not cause a prolonged deterioration in lung function. The nature and severity of episodes vary widely within and among individuals and can be influenced by multiple factors (Table 3). Common clinical symptoms include coughing, wheezing, shortness of breath, excessive mucus production, chest tightness, chest pain or an itching or scratching sensation in the chest. Less common symptoms include stomach pain, nausea;119 and near-death experiences.120 EIB/EIA has been shown to appear during prolonged exercise causing a lack of endurance despite conditioning. It may influence athletic performance 120,121 and often results in a prolonged recovery time following exercise. 119 A small subset of individuals experience a second, late-phase constriction 4 to 12 hours after the initial activity. This constriction is generally less severe than the first, but the magnitude of the two episodes are significantly correlated.108 No single factor predicts who will experience a late response, and these responses do not happen consistently in the same individuals.108,122

Table 3 Factors that may influence the severity of EIB/EIA

Factor | Decrease EIB/EIA | Increase EIB/EIA
Environmental conditions | Warm temperatures (34–37° C)124 High humidity (100%) Absence of allergens Low air pollution | Cold temperatures, dry air 124,125 Airborne particles and pollutants, allergens, moulds, dust Irritants: automobile exhaust, sulphur dioxide, nitrogen dioxide, smoke, ozone,126 chlorine127
Type, intensity, duration of Exercise | Short episodes of fast/slow running with brief rests128 VO_2_ max <40% predicted129 <3 minutes continuous exercise | Continuous activities that require near maximum aerobic capacity VO_2_ max ≥60% predicted 6–8 minutes continuous exercise
Overall control of underlying asthma and BHR | Good control: FEV_1_ >70% predicted Fall in BHR130 | Poor control: FEV_1_ <65% predicted Increase in BHR130
Physical conditioning | Good physical conditioning Warmup and cooldown sessions | Poor physical conditioning Sudden burst of activity Fatigue126 Emotional stress126 Athletic overtraining126
Respiratory tract infections, especially viral | No respiratory tract infections | Presence of respiratory tract infections126 Sinusitis130 Rhinitis
Time since last exercise | If within 40–90 min may benefit from refractory period130 | >2–3 hr
Concurrent medications | Maintenance anti-inflammatory bronchodilator medication | Salicylates, NSAIDS, β-blockers130
Pre-exercise foods eaten | None | Peanuts, celery, shrimp, grain, carrots, bananas130

BHR = bronchial hyperresponsiveness

Approximately 40 to 50 percent of individuals who have an initial episode of EIB/EIA experience a refractory period that is defined as “a period of diminished responsiveness when a second period of exercise follows in 1 to 4 hours.”8 During this time the magnitude of the EIB/EIA response to an identical exercise task may be less than 50 percent of the initial response.123 This phenomenon is somewhat elusive as it can be present at some times but not at others. The cause is not fully understood but it has been suggested that depletion of catecholamines, increased circulation of prostaglandin, and degranulation of mast cell mediators play a role.

## Magnitude and Importance of the Condition

According to National Center for Health Statistics estimates, approximately 20.5 million Americans (seven percent) have asthma.5 Asthma is reported to have resulted in 4,099 deaths in 2003 and 1.8 million emergency department visits in 2004.^5,131,132^ Between 60 to 90 percent of people with asthma experience EIA and consider exercise a major trigger of their asthma symptoms.133 Some claim that all asthmatics will experience EIA if ventilation is sufficiently high.6 Prevalence of EIB is lower (six to 13 percent) in a population with no history of asthma or allergy.8,9

EIB/EIA gained considerable attention following the 1972 Olympic Games when a gold medalist swimmer, Rick Demont, had his medal rescinded because he took oral ephedrine prior to the race to control his EIB/EIA. Since then, several studies conducted among athletes have reported the prevalence of EIB/EIA to range from 11 to 50 percent.7 Helenius and Haahtela9 estimated that the prevalence in summer sport athletes was between 3.7 to 22.8 percent, whereas among winter sport athletes the estimate ranged from 2.8 to 54.8 percent.134 High level endurance training in sports such as cross-country skiing, swimming, and long distance running may increase bronchial hyper-responsiveness (BHR) and cause inflammation in the airways because these athletes are repeatedly exposed to cold air, inhaled irritants, and allergens.135

Asthma is known to have a negative impact on health-related quality of life.136 The threat of an asthma attack may result in withdrawal from physical and social activities, which can lead to deconditioning, weight gain, and to an altered sense of self-esteem.137 Both recreational and elite athletes tend to minimize or deny symptoms due to embarrassment, fear of repercussions, or lack of understanding of what they are experiencing.8,138 EIB/EIA and asthma have an impact on quality of life. The fear of sudden breathlessness creates a sense of panic, which may prevent children and adults from participating in sports and cause parents of children with asthma to impose restrictions.10 Fear of failure and sub-optimal performance in sports may lead many individuals suffering from EIB/EIA to opt for sedentary activities.120

Unrecognized EIB/EIA can result in serious public health consequences. Data compiled from coroners reports for deaths between 1993 to 2000 indicated that, among 61 asthma-related deaths occurring in close relation to physical activity, about 80 percent occurred in individuals younger than 21 years of age. More than half of all asthma-related deaths occurred in individuals who were considered to be elite or competitive athletes, nearly 10 percent of which occurred in individuals with no known history of asthma.139

## Diagnosis of Exercise-Induced Bronchoconstriction and Asthma

Potential EIB/EIA can be detected by taking a thorough medical history. EIB/EIA is suspected when individuals, who otherwise have good lung function, complain of recurrent shortness of breath and symptoms of cough, wheeze, chest pain, or prolonged recovery time following exercise. These symptoms are independent of a person’s conditioning level. If symptoms are relieved by inhaling a short-acting beta-agonist (SABA) or if symptoms are prevented by taking a SABA before exercise, a diagnosis of EIB/EIA is strongly supported.118 The degree of airway constriction can be measured objectively by a spectrum of pulmonary function tests; however, most clinicians and laboratories use the FEV_1_7 or, very occasionally, the peak expiratory flow (PEF).

When a patient’s history suggests EIB/EIA, measuring the change in FEV_1_ before and after a standardized exercise challenge test (ECT) on a treadmill or bicycle ergometer can assist in making the diagnosis. The American Thoracic Society (ATS) has published guidelines for conducting a standardized ECT,18 which include recommendations for environmental control, as well as the level and duration of intensity required to ensure a sufficiently vigorous challenge. Minute ventilation must reach the target level in the first 4 minutes of the challenge.

The standardized laboratory ECT has not always demonstrated sufficient sensitivity to identify EIB/EIA in elite athletes who perform in many venues and with widely varying intensity and duration, therefore, other surrogate tests have been recommended.140 Some of the current options include sport specific challenges, the free running asthma screening test (FRAST), measures of direct bronchial responsiveness to methacholine (MCH) and indirect responsiveness to eucapnic voluntary hyperpnea (EVH) or mannitol.

In the general population, vigorous exercise should cause little to no prolonged decrease in airflow following exercise. A decrease of 10 percent from baseline has been shown to be a change greater than two standard deviations from the normal response.141 In 2001, prior to the Salt Lake City Olympics, the International Olympic Committee Medical Commission met to determine the parameters for EIB/EIA. They accepted a cutpoint of a fall of 10 percent or more in FEV_1_, as suggested by the European Respiratory Society and ATS guidelines.18,142 This decision was supported by a study indicating a coefficient of variation of six percent for repeated maneuvers of FEV_1_.143 However, the cutpoint value is a subject of ongoing debate. Two investigators have suggested that a fall in FEV_1_ of only 6.5 percent is appropriate.144,145 Anderson et al. claim that the 10 percent value is justified as this level of constriction could potentially limit exercise performance.140,145 A 10 percent fall is also supported by Hurwitz et al. who found this degree of constriction to have a specificity of 90 percent for identifying those with asthma.146

By convention EIB/EIA is quantified using the maximum percent fall index, which is the maximum reduction in lung function post-exercise, expressed as a percent of the pre-exercise value. The index is calculated using the formula:

(F E V_1_ / P E F_p r e - e x e r c i s e_ - minimum F E V_1_ / P E F_p o s t - e x e r c i s e_)/(F E V_1_ / P E F_p o s t - e x e r c i s e_) × 100

A fall of 10 percent or greater on an ECT indicates that the individual has EIB/EIA. The greater the reduction in FEV_1_, the more severe the EIB/EIA episode is. If a person takes a prophylactic dose of a medication to control EIB/EIA, “complete protection” is achieved if the percent fall index is less than 10 percent.147

A significant placebo effect has been observed in randomized trials comparing an active pre-exercise treatment to placebo. Some participants have obtained either complete protection from EIB/EIA or significant attenuation of it with the placebo alone. Therefore, it is customary to subtract the fall in FEV_1_ on the active drug from the fall experienced on placebo and calculate the “clinical protection index” (the degree of protection afforded by a drug expressed as a percent of that offered by placebo) using the following formula:

(maximum % fall F E V_1 ( placebo )_ - maximum % fall F E V_1 ( treatment )_)/(maximum % fall F E V_1 ( placebo )_) × 100

A result of 50 percent or more is regarded as clinically significant.122

## Treatment of Exercise-Induced Bronchoconstriction and Asthma

The goal of treatment is to prevent or, at least, to reduce the severity of the bronchoconstriction and symptoms so that an individual can participate in any activity, regardless of its intensity and duration, without serious respiratory limitations. Through a combination of education, a commitment to fitness, pharmacologic intervention, and use of nonpharmacologic strategies, EIB/EIA can be successfully managed in the majority of cases. Different pharmaceutical agents that appear to operate on different phases of the response can provide at least partial relief from EIB/EIA.125 The most commonly used agents are inhaled SABA and long-acting beta-agonist (LABA) agents. Other agents include mast cell stabilizing agents (MCS), short-acting anticholinergics (SAAC), leukotriene receptor antagonists (LTRA), and inhaled corticosteroids (ICS). Theophyllines,148–150 antihistamines,151–153 calcium channel blockers,79,154 heparin,155 and furosemide155–158 have also been shown to have some degree of effectiveness.

There are many unresolved issues with respect to the treatment of EIB/EIA with pharmaceutical agents. There is concern that the continuous use of the SABA and LABA agents to control asthma over the long term could lead to a decrease in efficacy when also used prophylactically to control EIA. A development of tolerance, or tachyphylaxis, to SABA or LABA agents may not only decrease their protective effect, but also shorten their duration of action.62 In the case of SABAs, a serious concern is that continuous use will decrease its impact as a rescue medication in the case of severe EIA.

## Objective of this Evidence Report

The objective of this report was to synthesize the evidence to answer six key questions on diagnostic testing for EIB/EIA and six key questions on therapy for EIB/EIA (five involving pharmaceutical interventions and one a nonpharmacologic intervention).

### The Key Questions

The key questions for the diagnostic test accuracy review were as follows:

D–1. In patients with suspected EIB/EIA, what are the diagnostic test characteristics of a self-reported history/symptoms diary for diagnosing EIB/EIA compared with a standardized exercise challenge?

D–2. In patients with suspected EIB/EIA, what are the diagnostic test characteristics of a methacholine challenge for diagnosing EIB/EIA compared with a standardized exercise challenge?

D–3. In patients with suspected EIB/EIA, what are the diagnostic test characteristics of sport/venue specific exercise challenges for diagnosing EIB/EIA compared with a standardized exercise challenge?

D–4. In patients with suspected EIB/EIA, what are the diagnostic test characteristics of eucapnic voluntary hyperpnea for diagnosing EIB/EIA compared with a standardized exercise challenge?

D–5. In patients with suspected EIB/EIA, what are the diagnostic test characteristics of a free running asthma screening test (FRAST) for diagnosing EIB/EIA compared with a standardized exercise challenge?

D–6. In patients with suspected EIB/EIA, what are the diagnostic test characteristics of mannitol for diagnosing EIB/EIA compared with a standardized exercise challenge?

The key questions for the therapy review were as follows:

T–1. In patients with confirmed EIB/EIA, do patients using SABA or LABA therapy develop tachyphylaxis to treatment and, if so, at what frequency, compared with standard comparator treatments and/or placebo?

T–2. In patients with confirmed EIB/EIA, does pre-exercise treatment with leukotriene receptor antagonists therapy reduce symptoms and prevent a 10 percent or more drop in FEV_1_ compared with no treatment/placebo?

T–3. In patients with confirmed EIB/EIA, does pre-exercise treatment with inhaled corticosteroid therapy reduce symptoms and prevent a 10 percent or more drop in FEV_1_ compared with no treatment/placebo?

T–4. In patients with confirmed EIB/EIA, does pre-exercise treatment with mast cell stabilizers (sodium cromoglycate or nedocromil) therapy reduce symptoms and prevent a 10 percent or more drop in FEV_1_ compared with no treatment/placebo?

T–5. In patients with confirmed EIB/EIA, does pre-exercise treatment with anticholinergics (ipratropium) therapy reduce symptoms and prevent a 10 percent or more drop in FEV_1_ compared with no treatment/placebo?

T–6. In patients with confirmed EIB/EIA, does a refractory period (10 to 15 minute warmup and/or cooldown) reduce symptoms and prevent a 10 percent or more drop in FEV_1_ compared with no treatment/placebo?