# Studies Investigating Mast Cell Stabilizing Agents

The following 44 studies were included in three systematic reviews and two subsequent publications that investigated mast cell stabilizing agents.72–75 Six of the studies in this list addressed one or more of the other key questions of this current report; they have been marked with an asterisk (*). Nine studies did not meet the inclusion criteria for this current report; most were excluded because they were not published in English or were not randomized controlled trials. These studies have been marked with a †.

- 1. Boner AL, Vallone G, Bennati D. Nedocromil sodium in exercise-induced bronchoconstriction in children. Ann Allergy 1989;62(1):38–41.
- 2. Boner AL, Miglioranzi P, Piacentini G, et al. Effects of nedocromil sodium pressurized aerosol on exercise challenge using a spacer device and the normal adapter. Pediatr Asthma Allergy Immunol 1988;2(3):207–15.
- *3. Boulet LP, Turcotte H, Tennina S. Comparative efficacy of salbutamol, ipratropium, and cromoglycate in the prevention of bronchospasm induced by exercise and hyperosmolar challenges. J Allergy Clin Immunol 1989;83(5):882–7.
- 4. Bundgaard A, Enehjelm SD, Schmidt A. A comparative study of the effects of two different doses of nedocromil sodium and placebo given by pressurised aerosol in exercise-induced bronchoconstriction. Allergy 1988;43(7):493–6.
- *5. Bundgaard A, Rasmussen FV, Madsen L. Pretreatment of exercise-induced asthma in adults with aerosols and pulverized tablets. Allergy 1980;35(8):639–45.
- 6. Bundgaard A, Buch D, Schmidt A, et al. Pretreatment of exercise-induced asthma in children using disodium cromoglycate and fenoterol inhalation powder. Eur J Respir Dis Suppl 1983;130:36–41.
- 7. Bundgaard A, Schmidt A. Pretreatment of exercise-induced asthma by disodium cromoglycate and fenoterol. Eur J Respir Dis Suppl 1983;128(Pt 2):521–5.
- 8. Bundgaard A. Exercise-induced asthma. Eur J Respir Dis 1980;68(Suppl 143):51–6.
- 9. Chudry N, Correa F, Silverman M. Nedocromil sodium and exercise induced asthma. Arch Dis Child 1987;62(4):412–4.
- 10. Clarke PS, Ratowsky DA. Effect of fenoterol hydrobromide and sodium cromoglycate individually and in combination on postexercise asthma. Ann Allergy 1990;64(2 Pt 2):187–90.
- 11. Comis A, Valletta EA, Sette L, et al. Comparison of nedocromil sodium and sodium cromoglycate administered by pressurized aerosol, with and without a spacer device in exercise-induced asthma in children. Eur Respir J 1993;6(4):523–6.
- 12. De Benedictis FM, Tuteri G, Niccoli A, et al. The effect of cromolyn sodium and nedocromil sodium administered by a pressurized aerosol with a spacer device on exercise-induced asthma in children. Mediators Inflamm 1994;3(Suppl 1):S35–7.
- 13. De Benedictis FM, Tuteri G, Bertotto A, et al. Comparison of the protective effects of cromolyn sodium and nedocromil sodium in the treatment of exercise-induced asthma in children. J Allergy Clin Immunol 1994;94(4):684–8.
- 14. De Benedictis FM, Tuteri G, Pazzelli P, et al. Cromolyn versus nedocromil: duration of action in exercise-induced asthma in children. J Allergy Clin Immunol 1995;96(4):510–4.
- ^†^15. De Benedictis FM, Tuteri G, Pazzelli P, et al. Combination drug therapy for the prevention of exercise-induced bronchoconstriction in children. Ann Allergy Asthma Immunol1998;80(4):352–6.
- 16. Debelic M. Nedocromil sodium and exercise-induced asthma in adolescents. Eur J Respir Dis 1986;69(Suppl 147):266–7.
- 17. Debelic M, Hertel G, Konig J. Double-blind crossover study comparing sodium cromoglycate, reproterol, reproterol plus sodium cromoglycate, and placebo in exercise-induced asthma. Ann Allergy 1988;61(1):25–9.
- *18. Dorward AJ, Patel KR. A comparison of ketotifen with clemastine, ipratropium bromide and sodium cromoglycate in exercise-induced asthma. Clin Allergy 1982;12(4):355–61.
- ^†^19. Gehrke I, Bohm E, Sybrecht GW. [Stress-induced asthma--placebo-controlled double-blind comparison of prevention using fenoterol, disodium cromoglycate and a combination of the two]. Prax Klin Pneumol 1986;40(4):129–34. German.
- ^†^20. Godfrey S, Konig P. Suppression of exercise-induced asthma by salbutamol, theophylline, atropine, cromolyn, and placebo in a group of asthmatic children. Pediatrics 1975;56(5 Suppl):930–4.
- *21. Godfrey S, Konig P. Inhibition of exercise-induced asthma by different pharmacological pathways. Thorax 1976;31(2):137–43.
- 22. Henriksen JM. Effect of nedocromil sodium on exercise-induced bronchoconstriction in children. Allergy 1988;43(6):449–53.
- 23. Konig P, Hordvik NL, Kreutz C. The preventive effect and duration of action of nedocromil sodium and cromolyn sodium on exercise-induced asthma EIA in adults. J Allergy Clin Immunol 1987;79(1):64–8.
- 24. Morton AR, Ogle SL, Fitch KD. Effects of nedocromil sodium, cromolyn sodium, and a placebo in exercise-induced asthma. Ann Allergy 1992;68(2):143–8.
- *25. Neijens HJ, Wesselius T, Kerrebijn KF. Exercise-induced bronchoconstriction as an expression of bronchial hyperreactivity: a study of its mechanisms in children. Thorax 1981;36(7):517–22.
- 26. Novembre E, Frongia G, Lombardi E, et al. The preventive effect of nedocromil or furosemide alone or in combination on exercise-induced asthma in children. J Allergy Clin Immunol 1994;94(2 Pt 1):201–6.
- 27. Novembre E, Frongia GF, Veneruso G, et al. Inhibition of exercise-induced-asthma EIA by nedocromil sodium and sodium cromoglycate in children. Pediatr Allergy Immunol 1994;5(2):107–10.
- 28. Obata T, Matsuda S, Akasawa A, et al. Preventive effect and duration of action of disodium cromoglycate and procaterol on exercise-induced asthma in asthmatic children. Ann Allergy 1993;70(2):123–6.
- 29. Oseid S, Mellbye E, Hem E. Effect of nedocromil sodium on exercise-induced bronchoconstriction exacerbated by inhalation of cold air. Scand J Med Sci Sports 1995;5(2):88–93.
- ^†^30. Pichaipat V, Tongpenyai Y, Nerntong T, et al. The protective effect of inhaled terbutaline, sodium cromoglycate and budesonide on exercise-induced asthma in children. J Med Assoc Thai 1995;78(10):505–8.
- 31. Roberts JA, Thomson NC. Attenuation of exercise-induced asthma by pretreatment with nedocromil sodium and minocromil. Clin Allergy 1985;15(4):377–81.
- ^†^32. Rohr AS, Siegel SC, Katz RM, et al. A comparison of inhaled albuterol and cromolyn in the prophylaxis of exercise-induced bronchospasm. Ann Allergy 1987;59(2):107–9.
- 33. Shaw RJ, Kay AB. Nedocromil, a mucosal and connective tissue mast cell stabilizer, inhibits exercise-induced asthma. Br J Dis Chest 1985;79(4):385–9.
- 34. Sinclair DG, Winfield CR. Attenuation of exercise induced asthma by nedocromil sodium and sodium cromoglycate. J R Army Med Corps 1990;136(2):105–6.
- ^†^35. Spada EL, Donner CF, Meriggi A, et al. [Pharmacologic prevention of exercise-induced asthma]. Minerva Pneumol 1985;24(2):159–64. Italian.
- ^†^36. Svenonius E, Arborelius M, Wiberg R, et al. A comparison of terbutaline inhaled by Turbuhaler and by a chlorofluorocarbon CFC inhaler in children with exercise-induced asthma. Allergy 1994;49(6):408–12.
- 37. Thomson NC, Roberts JA. Nedocromil sodium attenuates exercise-induced asthma. Eur J Respir Dis 1986;69(Suppl 147):297–8.
- *38. Thomson NC, Patel KR, Kerr JW. Sodium cromoglycate and ipratropium bromide in exercise-induced asthma. Thorax 1978;33(6):694–9.
- 39. Todaro A, Faina M, Alippi B, et al. Nedocromil sodium in the prevention of exercise-induced bronchospasm in athletes with asthma. J Sports Med Phys Fitness 1993;33(2):137–45.
- *40. Tullett WM, Patel KR, Berkin KE, et al. Effect of lignocaine, sodium cromoglycate, and ipratropium bromide in exercise-induced asthma. Thorax 1982;37(10):737–40.
- ^†^41. Vazquez C, Fidalgo I, Virto MC, et al. [Effectiveness of disodium cromoglycate, salbutamol, and ipratropium bromide in the inhibition of exercise-induced bronchospasm]. An Esp Pediatr 1984;20(8):756–62. Spanish.
- 42. Vilsvik J, Schaanning J. A comparative study of the effect of three doses of nedocromil sodium and placebo given by pressurized aerosol to asthmatics with exercise-induced bronchoconstriction. Ann Allergy 1988;61(5):367–70.
- 43. Woolley M, Anderson SD, Quigley BM. Duration of protective effect of terbutaline sulfate and cromolyn sodium alone and in combination on exercise-induced asthma. Chest 1990;97(1):39–45.
- 44. Zanconato S, Baraldi E, Santuz P, et al. Effect of inhaled disodium cromoglycate and albuterol on energy cost of running in asthmatic children. Pediatr Pulmonol 1990;8:240–4.

The following 33 studies investigated mast cell stabilizing agents but were not included in three previous systematic reviews.

1. Bar-Yishay E, Gur I, Levy M, et al. Duration of action of sodium cromoglycate on exercise induced asthma: comparison of 2 formulations. Arch Dis Child 1983;58(8):624–7.
2. Bauer CP. The protective effect of nedocromil sodium in exercise-induced asthma. Eur J Respir Dis 1986;69(Suppl 147):252–4.
3. Ben-Dov I, Bar-Yishay E, Godfrey S. Heterogeneity in the response of asthmatic patients to pre-exercise treatment with cromolyn sodium. Am Rev Respir Dis 1983;127(1):113–6.
4. Bianco S, Moavero E, Robuschi M, et al. Prevention of PGF2alpha induced bronchoconstriction by disodium cromoglycate in asthmatic patients. IRCS Med Sci Clin Med 1976;4(4):147.
5. Brooks CD, Nelson AL, Metzler C. Attenuation of protection with repeated cromolyn dosing before exercise challenge in subjects with asthma. J Clin Pharmacol 1986;26(2):91–6.
6. Bundgaard A, Bach-Mortensen N, Schmidt A. The effect of sodium cromoglycate delivered by Spinhaler and by pressurized aerosol on exercise-induced asthma in children. Clin Allergy 1982;12(6):601–5.
7. Calvayrac P, Leophonte P, Fuseiller A, et al. Reduction of bronchial hyperreactivity and exercise-induced bronchospasm in children treated for one month with a pressurized sodium cromoglycate aerosol. Curr Ther Res Clin Exp 1991;49(3):422–35.
8. Corkey C, Mindorff C, Levison H, et al. Comparison of three different preparations of disodium cromoglycate in the prevention of exercise-induced bronchospasm: a double-blind study. Am Rev Respir Dis 1982;125(6):623–6.
9. Dahl R, Henriksen JM. Effect of oral and inhaled sodium cromoglycate in exercise-induced asthma. Allergy 1980;35(4):363–5.
10. Dahl R, Henriksen JM. Inhibition of exercise-induced bronchoconstriction by nebulised sodium cromoglycate in patients with bronchial asthma. Scand J Respir Dis 1979;60(2):51–5.
11. De Cree J, Verhaegen H, Geukens H, et al. Exercise-induced asthma. The comparative acute effects of oxatomide, placebo and sodium cromoglycate. Clin Trials J 1980;17(3):84–91.
12. De Fuccio MB, Neder JA, Dal CS, et al. Rapidly-incremental versus constant work rate protocols to investigate exercise-induced bronchospasm [abstract]. American Thoracic Society 99th International Conference 2003;B118.
13. Fu YX, Ye ST, Xia LY. The effect of sodium crompromate in the prevention of exercise- induced asthma. Asian Pac J Allergy Immunol 1985;3(2):147–50.
14. Jones RM, Horn CR, Lee DV, et al. Bronchodilator effects of disodium cromoglycate in exercise-induced bronchoconstriction. Br J Dis Chest 1983;77(4):362–9.
15. Morton AR, Ogle SL, Fitch KD. A comparison of nedocromil sodium, sodium cromoglycate and a placebo in the prevention of exercise induced asthma. Sports Med News 1991;9(1):4–5.
16. Morton AR, Fitch KD. Sodium cromoglycate BP in the prevention of exercise-induced asthma. Med J Aust 1974;2(5):158–62.
17. Patel KR, Wall RT. Dose-duration effect of sodium cromoglycate aerosol in exercise-induced asthma. Eur J Respir Dis 1986;69(4):256–60.
18. Patel KR, Berkin KE, Kerr JW. Dose-response study of sodium cromoglycate in exercise- induced asthma. Thorax 1982;37(9):663–6.
19. Patel KR. Sodium cromoglycate and verapamil alone and in combination in exercise induced asthma. Br Med J (Clin Res Ed) 1983;286(6365):606.
20. Rasmussen FV, Madsen L, Bundgaard A. Combined effect of an anticholinergic drug ipratropium bromide and disodium cromoglycate in exercise induced asthma. Scand J Respir Dis Suppl 1979;103:159–62.
21. Robuschi M, Riva E, Fuccella LM, et al. Prevention of exercise-induced bronchoconstriction by a new leukotriene antagonist SK&F 104353. A double-blind study versus disodium cromoglycate and placebo. Am Rev Respir Dis 1992;145(6):1285–8.
22. Schoeffel RE, Anderson SD, Lindsay DA. Sodium cromoglycate as a pressurised aerosol vicrom in exercise-induced asthma. Aust N Z J Med 1983;13(2):157–61.
23. Shaw RJ, Kay AB. Nedocromil sodium, a mucosal and connective tissue mast cell stabilizer, inhibits exercise-induced asthma. Eur J Respir Dis 1986;69(Suppl 147):294–6.
24. Silverman M, Turner WM. Exercise induced asthma: response to disodium cromoglycate in skin-test positive and skin-test negative subjects. Clin Allergy 1972;2(2):137–42.
25. Silverman M, Connolly NM, Balfour-Lynn L, et al. Long-term trial of disodium cromoglycate and isoprenaline in children with asthma. Br Med J 1972;3(823):378–81.
26. Sly RM. Effect of cromolyn sodium on exercise-induced airway obstruction in asthmatic children. Ann Allergy 1971;29(7):362–6.
27. Storms W. Double-blind, placebo-controlled study of single doses of chlorofluorocarbon (CFC) and CFC-free cromolyn sodium for exercise-induced bronchoconstriction. Curr Ther Res Clin Exp 1999;60(12):629–37.
28. Tullett WM, Tan KM, Wall RT, et al. Dose-response effect of sodium cromoglycate pressurised aerosol in exercise induced asthma. Thorax 1985;40(1):41–4.
29. Umeno E, Nishima S. Investigation of the inhibiting mechanism of disodium cromoglycate in exercise-induced bronchospasm. Arerugi 1985;34(5):320–8.
30. Valero A, Garrido E, Malet A, et al. Exercise- induced asthma prophylaxis in athletes using inhaled nedocromil sodium. Allergol Immunopathol (Madr) 1996;24(2):81–6.
31. Viallat JR, Razzouk H, Edmond F. Double-blind study of the preventive action of sodium cromoglycate on the exercise induced bronchospasm in children. Rev Fr Allergol Immunol Clin 1986;26(3):121–4.
32. Vidgren M, Silvasti M, Vidgren P, et al. Physical properties and clinical efficacy of two sodium cromoglycate inhalation aerosol preparations. Acta Pharm Nord 1991;3(1):1–4.
33. Weiner P, Saaid M, Reshef A. Isotonic nebulized disodium cromoglycate provides better protection against methacholine- and exercise-induced bronchoconstriction. Am Rev Respir Dis 1988;137(6):1309–1.