# Excluded Studies

## Diagnosis of EIB/EIA reviews

402 studies were excluded from the diagnostic test accuray reviews. Reasons for exclusion include: study design (n=116), population (n=8), no reference standard (n=21), no comparison (n=46), did not diagnose EIA/EIB (n=158), insufficient data (n=26), other diagnostic tests (n=24), duplicate publication (n=2), and language (n=1). In addition, we were unable to obtain copies of 10 studies.

## Study Design (n = 116)

1. Bronchial asthma. Med Sport (Roma) 2006;59(1):25–42.
2. No perfect screening test for asthma. Sports Med Digest 1999;21(6):64–5.
3. Albers M, Schermer T, Van WC. Airflow limitation as a screening tool: too relevant to ignore, too conspicuous to apply? Chest 2005;128(4):1898–900.
4. Amirav I. Airway response to methacholine during exercise induced refractoriness in asthma. Thorax 1987;42(10):831.
5. Anderson SD, Argyros GJ, Magnussen H, Holzer K. Provocation by eucapnic voluntary hyperpnoea to identify exercise induced bronchoconstriction. Br J Sports Med 2001;35(5):344–7.
6. Anderson SD, Silverman M, Tai E, Godfrey S. Specificity of exercise in exercise-induced asthma. Br Med J 1971;4(5790):814–5.
7. Anthonisen NR. Asthma questionnaires. Can Respir J 2007;14(2):77–8.
8. Ashbaugh SJ, Rubino I, Rose VL. At-risk athletes should be screened for exercise-induced asthma. Am Fam Physician 1998;57(2):332.
9. Barbosa e Silva O, Ribeiro Saraiva LC. Exercise test indications in children and adolescents. Rev Bras Med Esporte 2004;10(5):420–3.
10. Berglund E. Challenging an exercise challenge protocol [comment]. Eur Respir J 1994;7(10):1909.
11. Berman BA, Ross RN. Exercise-induced asthma. Cutis 1982;30(2):176.
12. Bierman CW. Management of exercise-induced asthma. Ann Allergy 1992;68(2):119–22.
13. Bokulic RE. Screening for exercise-induced asthma [comment]. J Pediatr 2002;141(3):306–8.
14. Bonini S, Brusasco V, Carlsen KH, et al. Diagnosis of asthma and permitted use of inhaled beta2‐ agonists in athletes. Allergy 2004;59(1):33–6. Erratum in: Allergy 2005;60(4):548.
15. Britton J. Bronchial Provocation testing. Clin Exp Allergy 1989;19(4):481–4.
16. Britton J, Tattersfield AE. Does measurement of bronchial hyperreactivity help in the clinical diagnosis of asthma? Eur J Respir Dis 1986;68(4):233–8.
17. Brown J. Asthma in childhood. Med J Aust 1973;1(13):654–7.
18. Bruns AS, Parsons JP. Exercise-induced bronchospasm: diagnosis and treatment. J Clin Outcomes Manag 2007;14(4):211–9.
19. Buckley JM. Exercise-induced ‘asthma’. Hosp Pract 1979;14(7):118.
20. Bundgaard A. Exercise-induced asthma. Eur J Respir Dis Suppl 1986;143:51–6.
21. Busse WW. Exercise-induced asthma. Am J Sports Med 1981;9(3):194–6.
22. Cawley MJ. Exercise-induced asthma. J Pharm Pract 2003;16(1):59–67.
23. Chai H. Intermediary mechanisms in asthma. Some informal comments on the pathogenesis of the breathing disturbances. Clin Pediatr 1974;13(5):409–12.
24. Cherginets A, Cherginets V. Heterogeneity of bronchial response to exercise among children with asthma. Allergol Int 2001;50(2):179–87.
25. Cibor G. The diagnosis and management of exercise-induced asthma. Sports Medicine Alert 2001;7(8/9):49–52.
26. Cockcroft DW. Value of the diluent step in methacholine challenge tests. Ann Allergy Asthma Immunol 2002;89(1):4–6.
27. Colin A, Said E, Winter ST. Exercise-induced asthma in schoolchildren a pilot study in 2 Haifa districts Israel. Isr J Med Sci 1985;21(1):40–3.
28. Cotes JE, Reed JW. Recommendations on the use of exercise testing in clinical practice. Eur Respir J 2007;29(5):1064–6.
29. Crapo RO, Casaburi R, Coates AL, et al. Guidelines for methacholine and exercise challenge testing‐1999. This official statement of the American Thoracic Society was adopted by the ATS Board of Directors, July 1999. Am J Respir Crit Care Med 2000;161(1):309–29.
30. D’Urzo AD. Hypercapnia during exercise in asthmatic subjects [comment]. J Appl Physiol 1995;78(1):372.
31. Addo Yobo EOD, Custovic A, Taggart SCO, safo-Agyei AP, et al. Exercise induced bronchospasm in Ghana: prevalence in urban and rural children. Thorax 1996;51(Suppl 3):A42.
32. de Meer G, Marks GB, Postma DS. Direct or indirect stimuli for bronchial challenge testing: what is the relevance for asthma epidemiology? Clin Exp Allergy 2004;34(1):9–16.
33. Dempsey JA. Challenges for future research in exercise physiology as applied to the respiratory system. Exerc Sport Sci Rev 2006;34(3):92–8.
34. Dickinson JW, Whyte GP, McConnell AK, Nevill AM, et al. Mid-expiratory flow versus FEV1 measurements in the diagnosis of exercise induced asthma in elite athletes. Thorax 2006;61(2):111–4.
35. Djukanovic R. Is airways hyperreactivity selective or nonselective? Agents Actions 1993;43(Suppl):231–9.
36. Duiverman EJ. Asthma and lung function. Pediatr Pulmonol 2001;32(Suppl 23):141–2.
37. Ernst P, Nunes F, Gerardi G, Becklake MR. Distribution and determinants of bronchial hyperresponsiveness to exercise among primary school children. Am Rev Respir Dis 1992;145(4 Pt 2):A537.
38. Evans TM. Exercise-induced bronchoconstriction during room temperature and cold temperature exercise and eucapnic voluntary hyperventilation Marywood University; 2005.
39. Filipe MC, Delgado J, Rodrigues J, Vaz M. Exercise-induced respiratory symptoms: the utility of a free-athletic-sport test (“FAST”). Allergy (Copenhagen) 1998;53(Suppl 43):146.
40. Flint SE. Exercise-induced bronchospasms. J Pediatr Health Care 1990;4(3):147–8.
41. Gerhard H, Schachter EN. Exercise-induced asthma. Postgrad Med 1996;67(3):91–102.
42. Godfrey S, Konig P. Exercise-induced bronchial lability in atopic children and their families. Ann Allergy 1974;33(4):199–205.
43. Godfrey S, Koenig P. Exercise induced bronchial lability in wheezy children and their families. Pediatrics 1975;56(5 Suppl):851–5.
44. Godfrey S, Silverman M, Anderson SD. Problems of interpreting exercise-induced asthma. J Allergy Clin Immunol 1973;52(4):199–209.
45. Godfrey S. Proceedings: the clinical value of exercise tests in children. BTTA Rev 1973;3(4):75.
46. Godfrey S, Silverman M, Anderson SD. The use of the treadmill for assessing exercise induced asthma and the effect of varying the severity and duration of exercise. Pediatrics 1975;56(5 Suppl):893–8.
47. Goldberg S, Schwartz S, Izbicki G, et al. Sensitivity of exercise testing for asthma in adolescents is halved in the summer. Chest 2005;128(4):2408–11.
48. Gordon BR. Asthma history and presentation. Otolaryngol Clin North Am 2008;41(2):375–85.
49. Gotshall RW. Airway response during exercise and hyperpnoea in non-asthmatic and asthmatic individuals. Sports Med 2006;36(6):513–27.
50. Greaves IA. Exercise and asthma. Med J Aust 1977;2(25):819–20.
51. Hamilton B. Diagnosis and management of asthma in athletics. [Diagnostic et gestion de l’asthme en athletisme]. Modern Athlete and Coach 2003;41(2):19–20.
52. Hamilton B. Diagnosis and management of asthma in athletics [abstract]. NSA 2003;18(3):71.
53. Higenbottam T, Godden D. Inhalation challenge testing for asthma. Role of bronchial provocation tests in clinical practice. Postgrad Med 1984;76(5):161–4.
54. Holzer K, Anderson S, Douglass J. Exercise-induced bronchoconstriction in elite athletes: which diagnostic challenge test? [abstract]. J Sci Med Sport 2002;5(Suppl):124.
55. Holzer K, Douglass JA. Exercise induced bronchoconstriction in elite athletes: measuring the fall. [comment]. Thorax 2006;61(2):94–6.
56. Hosey RG, Phillips GC. Exercise-induced anaphylaxis: diagnosis and management. Int Sport Med J 2002;3(2):1–8.
57. Hunt CH. Exercise induced asthma. Del Med J 1987;59(9):609–10.
58. Hurwitz KM, Argyros GJ, Roach JM, Eliasson AH, et al. Interpretation of eucapnic voluntary hyperventilation in the diagnosis of asthma. Chest 1995;108(5):1240–5.
59. Kaldmae P. Pulmonary function tests for diagnosing exercise induced airway hyperreactivity in children. Acta Medica Baltica 1997;4(1):36–9.
60. Kennedy MF. Exercise and children with asthma [letter]. Can Fam Phys 2002;48:457–8.
61. Kyle JM, Hershberger SL, Leaman JR, Melrose JK. Exercise bronchospasm in recreational athletes. Phys Sportsmed 1997;25(5):E30.
62. Larussa J, Feinstein RA, Wang-Dohlman A. A simple test to identify exercise induced bronchospasm (EIB) in adolescent athletes. Pediatr Res 1993;33(4 Pt 2):6A.
63. Leaver-Dunn D, Robinson JB, Laubenthal J. Assessment of respiratory conditions in athletes. Athletic Ther Today 2000;5(6):14–9.
64. Leski M. Exercise-induced asthma. South Med J 2004;97(9):859–60.
65. Leuppi JD, Brannan JD, Anderson SD. Bronchial provocation tests: the rationale for using inhaled mannitol as a test for airway hyperresponsiveness. Swiss Med Wkly 2002;132(13–14):151–8.
66. Mannix ET, Farber MO. Distinguishing between exercise-induced asthma and deconditioning. J Respir Dis 2000;21(6):363–4.
67. Mayers LB, Rundell KW. Exercise-induced asthma. Olympic Coach 2000;10(3):12–4.
68. Mayol PM, Sifontes JE, Vazquez S, Rodriguez S, Jr. Exercise-induced asthma: preliminary report. Boletin - Asociacion Medica de Puerto Rico 1986;78(12):535–8.
69. McFadden J. Exercise-induced asthma. Recent approaches. Chest 1988;93(6):1282–3.
70. Meehan C. Asthma and diving screening protocols. S Pac Underw Med Soc J 2001;31(4):226–9.
71. Miller LC. Exercise-induced asthma. J Indiana State Med Assoc 1979;72(4):259–62.
72. Milne C. Provocation by eucapnic voluntary hyperpnoea to identify exercise induced bronchoconstriction [abstract]. New Zeal J Sports Med 2002;30(1):22–3.
73. Munyard PF, Bush A. Exercise, a fall in peak expiratory flow rate, and asthma: what is the connection? Clin Exp Allergy 1992;22(8):729–30.
74. Nemet D, Wolach B, Yacobovich J, Eliakim A. Exercise in childhood asthma: provoking agent, diagnostic tool and therapeutic measure. IMAJ 2000;2(2):99–103.
75. Oseid S, Aas K. Exercise-induced asthma. Allergy 1978;33(5):227–8.
76. Owens GR. Exercise-induced asthma: optimal testing methods and preventive measures. Consultant 1987;27(3):23.
77. Palange P, Ward SA, Carlsen KH, et al. Recommendations on the use of exercise testing in clinical practice. Eur Respir J 2007;29(1):185–209.
78. Parry DE, Lemanske RF. Exercise-induced asthma. Athletic Ther Today 1996;1(5):11–5.
79. Persaud Y, Lamm C, Silverman B, Schneider A. Misdiagnosis of exercise induced asthma in two patients years after surgical repair of congenital anomalies [abstract]. J Allergy Clin Immunol 2006;117(2 Suppl):S3.
80. Rachelefsky GS. Exercise-induced asthma. Sports Med Digest 1991;13(10):1–2.
81. Randolph C. The free running athletic screening test. Ann Allergy Asthma Immunol 1998;81(4):275a–g.
82. Randolph CC. Exercise-induced asthma, part 1: how to make the diagnosis. J Respir Dis 2002;23(7):387–90.
83. Randolph CC. Exercise-induced asthma, part 1: how to make the diagnosis. J Respir Dis Pediatr 2003;5(4):170–3.
84. Rebuck AS, Read J. Exercise-induced asthma. Lancet 1968;2(7565):429–31.
85. Rees J. ABC of asthma. Definition and diagnosis. Br Med J (Clin Res Ed) 1984;288(6427):1370–2.
86. Rund DA. Asthma. Phys Sportsmed 1990;18(1):143–4.
87. Rundell KW, Wilber RL, Szmedra L, Wang D. Laboratory EIA screening unreliable for elite athletes. Phys Sportsmed 2000;28(6):26.
88. Rundell KW. Screening elite winter athletes for exercise induced asthma: a comparison of three challenge methods: commentary. Br J Sports Med 2006;40(2):179–82.
89. Rupp NT. Diagnosis and management of exercise-induced asthma. Phys Sportsmed 1996;24(1):77–87.
90. Santilli G. Pulmonary function evaluation and physical activity. Med Sport (Roma) 2006;59(1):1.
91. Saranz R, Del Giacco GS, Croce VH, Del Giacco SR. Exercise-induced asthma: an update. Eur J Inflamm 2004;2(1):5–16.
92. Schoene ML. Conventional testing methods incapable of detecting breathing problems among elite athletes. Sports Med Digest 1999;21(6):61.
93. Schoene ML. Respiratory symptoms no indication of asthma among elite athletes. Sports Med Digest 2000;22(8):85–7.
94. Shapiro GG, Bierman CW. Exercise-induced asthma. J Asthma 1983;20(5):383–9.
95. Shapiro GG. Methacholine challenge - relevance for the allergic athlete. J Allergy Clin Immunol 1984;73(5 Suppl II):670–5.
96. Simons E. Repeat exercise normalizes the gas-exchange impairment induced by a previous exercise bout in asthmatic subjects: commentary. Pediatrics 2006;118(Suppl 1):S28–S29.
97. Simonsson BG, Skoogh BE, Ekstrom-Jodal B. Exercise-induced airway constriction. Thorax 1969;24(4):506.
98. Simpson G. Mannitol bronchial challenge testing and scuba diving. Diving and Hyperbaric Medicine 2006;36(4):231.
99. Slater JB, Slater EG. Exercise induced asthma. Sports Medicine Update 1996;11(3):26–9.
100. Souhrada JF, Zeballos RJ, Chai H, Souhrada M. Two types of responses to exercise and isocapnic hyperventilation in asthmatics. Eur J Respir Dis Suppl 1983;128(Pt 1):246–52.
101. Spector SL, Chai H. Bronchial exercise and oral challenge procedures. Bull N Y Acad Med 1981;57(7):572–81.
102. Stephens J, Paridon SM. Exercise testing in pediatrics. Pediatr Clin North Am 2004;51(6):1569–87.
103. Sterk PJ, Fabbri LM, Quanjer PH, et al. Airway responsiveness: standardized challenge testing with pharmacological, physical and sensitizing stimuli in adults. Eur Respir J Suppl 1993;6(16):53–83.
104. Sterk PJ, Martinez Fernando J, Celli Bartolome R. Bronchoprovocation testing. Pulmonary function and exercise testing. Semin Respir Crit Care Med 1998;19(4):317–24.
105. Stoloff SW. The role of history taking in the diagnosis of asthma. Hosp Pract 1996;31(10):155–6.
106. Storms WW. Exercise-induced asthma: diagnosis and treatment for the recreational or elite athlete. Med Sci Sports Exerc 1999;31(1):S33–8.
107. Storms WW. Exercise-induced asthma: diagnosis and treatment for the recreational or elite athlete. American Swimming 1999;(3):28–32.
108. Sukanich AC, Rogers KD, Fireman P. Free-running test for asthma screening in school children. Pediatr Res 1989;25(4 Pt 2):105A.
109. Svenonius E, Lecerof H, Lilja B, et al. The volume of trapped gas: a new and sensitive test for the detection of exercise-induced bronchospasm in children. Acta Paediatr Scand 1978;67(5):583–9.
110. Terblanche E, Stewart RI. The prevalence of exercise-induced broncho-constriction in Cape Town school children. S Afr Med J 1990;78(12):744–7.
111. Volcheck GW. In-office diagnosis of exercise-induced asthma. Postgrad Med 2000;107(2):48.
112. Weaver J, Denegar CR, Hertel J. Exercise-induced asthma. Athletic Ther Today 2000;5(3):38–42.
113. Weinstein R. Exercise-induced asthma. Ear Nose Throat J 1984;63(2):57–8.
114. Wheeler LS, Boyle S. Attempting to use a district-wide asthma case identification system for asthma prevalence. J Sch Health 2006;76(6):219–22.
115. Winslow DH. Exercise induced asthma. J Ky Med Assoc 1978;76(6):271–4.
116. Wolanczyk-Medrala A, Dor A, Szczepaniak W, Tomkowicz T, et al. Exercise-induced bronchospasm among athletes in Lower Silesia Province. J Sports Sci 2008;26(13):1467–71.

## Population (n = 8)

1. Belcher NG, Lee TH, Rees PJ. Airway responses to hypertonic saline, exercise and histamine challenges in bronchial asthma. Eur Respir J 1989;2(1):44–8.
2. Bundgaard A, Ingemann-Hansen T, Schmidt A, Halkjaer-Kristensen J. The importance of ventilation in exercise-induced asthma. Allergy 1981;36(6):385–9.
3. Glanville AR, Gabb GM, Theodore J, Robin ED. Bronchial responsiveness to exercise after human cardiopulmonary transplantation. Chest 1989;96(2):281–6.
4. Mapp CE, Boniotti A, Papi A, Maggi CA, et al. Effect of bumetanide on toluene diisocyanate induced contractions in guinea pig airways. Thorax 1993;48(1):63–7.
5. Reiff DB, Choudry NB, Pride NB, Ind PW. The effect of prolonged submaximal warm-up exercise on exercise-induced asthma. Am Rev Respir Dis 1989;139(2):479–84.
6. Stark RD, Gambles SA, Chatterjee SS. An exercise test to assess clinical dyspnoea: estimation of reproducibility and sensitivity. Br J Dis Chest 1982;76(3):269–78.
7. Vilozni D, Bentur L, Efrati O, et al. Exercise challenge test in 3- to 6-year-old asthmatic children. Chest 2007;132(2):497–503.
8. Waffler-Kammermann N, Lacorcia RS, Wettstein M, et al. A new standardized treadmill walking test requiring low motor skills in children aged 4–10 years. Pediatr Pulmonol 2008;43(2):187–95.

## No Reference Standard (n = 21)

1. Bavarian B, Mehrkhani F, Ziaee V, et al. Sensitivity and specificity of self-reported symptoms for exercise-induced bronchospasm diagnosis in children. Iran J Pediatr 2009;19(1):47–51.
2. Capao-Filipe M, Moreira A, Delgado L, et al. Exercise-induced bronchoconstriction and respiratory symptoms in elite athletes. Allergy 2003;58(11):1196.
3. Choi IS, Chung SW, Koh YI, et al. Airway hyperresponsiveness to hypertonic saline as a predictive index of exercise-induced bronchoconstriction. Korean J Intern Med 2005;20(4):284–9.
4. De Fuccio MB, Nery LE, Malaguti C, et al. Clinical role of rapid-incremental tests in the evaluation of exercise-induced bronchoconstriction. Chest 2005;128(4):2435–42.
5. Drobnic F, Casan P, Banquells M, et al. Cough after exercise in the elite athlete. Sports Med Train Rehabil 1996;6(4):309–15.
6. Durand F, Kippelen P, Ceugniet F, et al. Undiagnosed exercise-induced bronchoconstriction in ski-mountaineers. Int J Sports Med 2005;26(3):233–7.
7. Erhabor GE, Awotedu AA, Balogun MO. Exercise induced bronchoconstriction in Nigerian asthmatics. Afr J Med Med Sci 1993;22(2):33–7.
8. Fernandez-Nieto M, Rodriguez-Nieto M, Aguado E, et al. Aiway inflammation after mannitol challenge in elite athletes. Allergy (Oxford) 2009;64(Suppl 90):196.
9. Haby MM, Anderson SD, Peat JK, et al. An exercise challenge protocol for epidemiological studies of asthma in children: comparison with histamine challenge Eur Respir J 1994;7(1):43–9.
10. Hallstrand TS, Curtis JR, Koepsell TD, et al. Effectiveness of screening examinations to detect unrecognized exercise-induced bronchoconstriction. J Pediatr 2002;141(3):343–8.
11. Hammerman SI, Becker JM, Rogers J, et al. Asthma screening of high school athletes: identifying the undiagnosed and poorly controlled. Ann Allergy Asthma Immunol 2002;88(4):380–4.
12. Kaynar H, Akgun M, Saglam L, et al. The prevalence of exercise-induced bronchoconstriction among symptomatic sportsmen. Asian Pac J Allergy Immunol 2004;22(4):191–6.
13. Koh YI, Choi IS, Lim H. Atopy may be related to exercise-induced bronchospasm in asthma. Clin Exp Allergy 2002;32(4):532–6.
14. Mannix ET, Manfredi F, Farber MO. A comparison of two challenge tests for identifying exercise-induced bronchospasm in figure skaters. Chest 1999;115(3):649–53.
15. Randolph C, Mattasavage C, Fraser B. Screening of high school athletes for exercise asthma by free running test. J Allergy Clin Immunol 1996;97(1 Pt 3):378.
16. Randolph C, Fraser B, Matasavage C. The free running athletic screening test as a screening test for exercise-induced asthma in high school. Allergy Asthma Proc 1997;18(2):93–8.
17. Rundell KW, Spiering BA, Evans TM, et al. Baseline lung function, exercise-induced bronchoconstriction, and asthma-like symptoms in elite women ice hockey players. Med Sci Sports Exerc 2004;36(3):405–10.
18. Rundell KW, Anderson SD, Spiering BA, et al. Field exercise vs laboratory eucapnic voluntary hyperventilation to identify airway hyperresponsiveness in elite cold weather athletes. Chest 2004;125(3):909–15.
19. Spiering B, Rundell K, Anderson S, et al. Diagnosing exercise-induced bronchoconstriction in elite athletes: exercise vs. eucapnic voluntary hyperventilation [abstract]. Med Sci Sports Exerc 2003;35(5 Suppl):S10.
20. Stenfours N. A comparison of inhaled mannitol, metacholine provocation and eucapnic voluntary hyperventilation as diagnostic tests for exercised induced bronchoconstriction in cross country skiers [abstract]. European Respiratory Society Annual Congress, Berlin, Germany, October 4–8 2008:P1094.
21. Stensrud T, Mykland KV, Gabrielsen K, et al. Bronchial hyperresponsiveness in skiers: field test versus methacholine provocation? Med Sci Sports Exerc 2007;39(10):1681–6.

## No Comparison (n = 46)

1. Identifying asthma in young athletes. Phys Sportsmed 1996;24(6):42i.
2. Anderson SD, Brannan J, Spring J, et al. A new method for bronchial-provocation testing in asthmatic subjects using a dry powder of mannitol. Am J Respir Crit Care Med 1997;156(3):758–65.
3. Arbour K, Provost-Craig M, Sestili D, et al. Incidence of exercise-induced asthma in figure skaters [abstract]. Med Sci Sports Exerc 1993;25(5 Suppl):S180.
4. Balla K, Mezei G, Gyene I, et al. The running fitness of young asthmatic patients. Int Rev Allergol Clin Immunol 2007;13(2–3):38–43.
5. Bierman CW, Spiro SG, Petheram I. Characterization of the late response in exercise-induced asthma. J Allergy Clin Immunol 1984;74(5):701–6.
6. Boner A, Niero E, Antolini I, et al. Biphasic (early and late) asthmatic responses to exercise in children with severe asthma, resident at high altitude. Eur J Pediatr 1985;144(2):164–6.
7. Braback L, Kalvesten L, Sundstrom G. Prevalence of bronchial asthma among schoolchildren in a Swedish district. Acta Paediatr Scand 1988;77(6):821–5.
8. Carlsen KH, Engh G, Mork M. Exercise-induced bronchoconstriction depends on exercise load. Respir Med 2000;94(8):750–5.
9. Dahlen B, O’Byrne PM, Watson RM, et al. The reproducibility and sample size requirements of exercise-induced bronchoconstriction measurements. Eur Respir J 2001;17(4):581–8.
10. Eggleston PA, Guerrant JL. A standardized method of evaluating exercise-induced asthma. J Allergy Clin Immunol 1976;58(3):414–25.
11. Estela D, Sienra-Monge J, de la Paz H. Determinate the sensitivity and specificity exercise challenge on forced expiratory volume 1 second in obese and non obese children compared with asthmatic children [abstract]. J Allergy Clin Immunol 2003;111(2 Suppl):S140.
12. Falcao H, Almeida S, Gomes E. Treadmill exercise test in children: difficulties and relevance. Allergy (Oxford) 2007;62(Suppl 83).
13. Feinstein RA, Hains CS, Hemstreet MP, et al. A simple “step-test” protocol for identifying suspected unrecognized exercise-induced asthma (EIA) in children. Allergy Asthma Proc 1999;20(3):181–8.
14. Field J, Allegra J, Trautlein J, et al. Evaluation of exercise-induced bronchospasm in the adult asthmatic. J Allergy Clin Immunol 1976;58(5):575–80.
15. Freeman W, Weir DC, Sapiano SB, et al. The twenty-metre shuttle-running test: a combined test for maximal oxygen uptake and exercise-induced asthma? Respir Med 1990;84(1):31–5.
16. Hagan J, Millward D, Paul S, et al. The diagnosis of exercise induced bronchospasm and asthma in NCAA Division I athletes. Clin J Sport Med 2008;18(2):186.
17. Inbar O, Winstein Y, Daskalovic Y, et al. The effect of prone immersion on bronchial responsiveness in children with asthma. Med Sci Sports Exerc 1993;25(10):1098–102.
18. Jones NL. New tests to assess lung function. Exercise tesing in pulmonary evaluation: clinical applications. New Engl J Med 1975;293(13):647–50.
19. Kable S, Henry R, Sanson-Fisher R, et al. Childhood asthma: can computers aid detection in general practice? Br J Gen Pract 2001;51(463):112–6.
20. Kannisto S, Korppi M. Bronchial lability index in the diagnosis of asthma in children. Pediatr Asthma Allergy Immunol 1999;13(3):141–8.
21. Kannisto S, Vanninen E, Remes K, et al. Interrupter technique for evaluation of exercise-induced bronchospasm in children. Pediatr Pulmonol 1999;27(3):203–7.
22. Kippelen P, Caillaud C, Coste O, et al. Asthma and exercise-induced bronchoconstriction in amateur endurance-trained athletes. Int J Sports Med 2004;25(2):130–2.
23. Kukafka DS, Lang DM, Porter S, et al. Exercise-induced bronchospasm in high school athletes via a free running test: incidence and epidemiology. Chest 1998;114(6):1613–22.
24. Lumme A, Haahtela T, Ounap J, et al. Airway inflammation, bronchial hyperresponsiveness and asthma in elite ice hockey players. Eur Respir J 2003;22(1):113–7.
25. Lumme A, Haahtela T, Ounap J, et al. Airway inflammation, bronchial hyperresponsiveness, and asthma in elite ice hockey players. Med Sci Sports Exerc 2003;35(5 Suppl).
26. Nicklaus TM, Burgin WW Jr., Taylor JR. Spirometric tests to diagnose suspected asthma. Am Rev Respir Dis 1969;100:153–9.
27. Nicolaescu VV, Bozianu E, Manicatide MA, et al. Value of exercise test for the detection of bronchial asthma during field surveys in children. Rev Roum Med Intern 1974;11(2):207–13.
28. Nowak D, Kuziek G, Jorres R, et al. Comparison of refractoriness after exercise- and hyperventilation-induced asthma. Lung 1991;169(2):57–67.
29. Ogston J, Butcher JD. A sport-specific protocol for diagnosing exercise-induced asthma in cross-country skiers. Clin J Sport Med 2002;12(5):291–5.
30. Pearlman D, Anderson S, Charlton B, et al. Concordance of results from repeat exercise challenges. J Allergy Clin Immunol 2008;121(2 Suppl 1):S209.
31. Pierson WE, Bierman CW, Stamm SJ. Cycloergometer-induced bronchospasm. J Allergy 1969;43(3):136–44.
32. Pierson WE, Bierman CW. Free running test for exercise induced bronchospasm. Pediatrics 1975;56(5 Suppl):890–2.
33. Powell CV, White RD, Primhak RA. Longitudinal study of free running exercise challenge: reproducibility. Arch Dis Child 1996;74(2):108–14.
34. Rodriguez CH, Pimm PE, Shephard RJ, et al. Use of isovolume flow curves in the detection of exercise-induced bronchospasm. Respiration 1981;41(2):82–9.
35. Rosenthal RR, Laube BL, Jaeger JJ, et al. Methacholine sensitivity is unchanged during the refractory period following an exercise or isocapnic challenge. Am Rev Respir Dis 1984;129(4 Suppl):A250.
36. Rundell KW, Im J, Mayers LB, et al. Self-reported symptoms and exercise-induced asthma in the elite athlete. Med Sci Sports Exerc 2001;33(2):208–13.
37. Rupp NT, Brudno DS, Wagner JM, et al. Correlation of spirometric measures in the diagnosis of exercise induced asthma. J Allergy Clin Immunol 1992;89(1):232.
38. Schachter EN, Kreisman H, Littner M, et al. Airway responses to exercise in mild asthmatics. J Allergy Clin Immunol 1978;61(6):390–8.
39. Scott GC, Kung M, Nsari SJ. The reproducibility of paired spirograms following exercise-induced bronchoconstriction. Chest 1986;89(6 Suppl):499S.
40. Tsanakas JN, Milner RD, Bannister OM, et al. Free running asthma screening test. Arch Dis Child 1988;63(3):261–5.
41. Turcotte H, Langdeau JB, Bowie DM, et al. Are questionnaires on respiratory symptoms reliable predictors of airway hyperresponsiveness in athletes and sedentary subjects? J Asthma 2003;40(1):71–80.
42. Vacek L. Incidence of exercise-induced asthma in high school population in British Columbia. Allergy Asthma Proc 1997;18(2):89–91.
43. Varga EM, Eber E, Zach MS. Cold air challenge for measuring airway reactivity in children: lack of a late asthmatic reaction. Lung 1990;168(5):267–72.
44. Vichyanond P, Anuraklekha P, Ruengruk S. Exercise-induced asthma among Thai asthmatic children. J Med Assoc Thailand 2002;85(Suppl 2):S579–S585.
45. Wagner JM, Rupp NT, Brudno DS, et al. Length of post-exercise assessment in the determination of exercise induced asthma. J Allergy Clin Immunol 1992;89(1 Pt 2):233.
46. Williams D, Bruton J, Wilson I. Screening a state middle school for asthma using the free running asthma screening test. Arch Dis Child 1993;69(6):667–9.

## Did Not Diagnose EIA/EIB (n = 158)

1. Ahad A, Sandila MP, Siddiqui NA, et al. Exercise-induced bronchospasm in male athletes at Karachi. J Ayub Med Coll Abbottabad 2003;15(4):29–33.
2. Ahad A, Sandila MP, Siddiqui NA. Prevalence of exercise-induced bronchospasm in national hockey players of Pakistan. J Pak Med Assoc 2004;54(2):96–9. Erratum in: J Pak Med Assoc. 2004 Apr;54(4):231
3. Amin R, Faeezi A, Kashef S, et al. Assesment of exercise induced asthma in asthmatic children. Allergy (Oxford) 2009;64(Suppl. 90).
4. Amirav I, Dowdeswell R, Webster T, et al. Exercise, regardless of induced bronchoconstriction or inspired air conditions, does not alter airway reactivity. Chest 1993;104(1):171–4.
5. Anderson SD, McEvoy JD, Bianco S. Changes in lung volumes and airway resistance after exercise in asthmatic subjects. Am Rev Respir Dis 1972;106(1):30–7.
6. Anderson SD, Schoeffel RE. Respiratory heat and water loss during exercise in patients with asthma. Effect of repeated exercise challenge. Eur J Respir Dis 1982;63(5):472–80.
7. Anderson SD, Fitch K, Perry CP, et al. Responses to bronchial challenge submitted for approval to use inhaled beta2-agonists before an event at the 2002 Winter Olympics. J Allergy Clin Immunol 2003;111(1):45–50.
8. Argyros GJ, Roach JM, Hurwitz KM, et al. The refractory period after eucapnic voluntary hyperventilation challenge and its effect on challenge technique. Chest 1995;108(2):419–24.
9. Avital A, Springer C, Bar-Yishay E, et al. Adenosine, methacholine, and exercise challenges in children with asthma or paediatric chronic obstructive pulmonary disease. Thorax 1995;50(5):511–6.
10. Barnes PJ, Brown MJ, Silverman M, et al. Circulating catecholamines in exercise and hyperventilation induced asthma. Thorax 1981;36(6):435–40.
11. Barnes PJ, Brown MJ. Venous plasma histamine in exercise- and hyperventilation-induced asthma in man. Clin Sci 1981;61(2):159–62.
12. Ben Dov I, Amirav I, Shochina M, et al. Effect of negative ionisation of inspired air on the response of asthmatic children to exercise and inhaled histamine. Thorax 1983;38(8):584–8.
13. Ben Dov I, Gur I, Bar-Yishay E, et al. Refractory period following induced asthma: contributions of exercise and isocapnic hyperventilation. Thorax 1983;38(11):849–53.
14. Berkman N, Avital A, Breuer R, et al. Exhaled nitric oxide in the diagnosis of asthma: comparison with bronchial provocation tests. Thorax 2005;60(5):383–8.
15. Berto JM, Lopez C, Pina JM, et al. Lung function and bronchial response to methacholine in young adults who had asthma in childhood. Ann Allergy 1993;70(1):40–3.
16. Bhagat RG, Grunstein MM. Comparison of responsiveness to methacholine, histamine, and exercise in subgroups of asthmatic children. Am Rev Respir Dis 1984;129(2):221–4.
17. Bollinger MB. A school-based case identification process for identifying inner city children with asthma: The Breathmobile program. Pediatrics 2005;116(2):560–1.
18. Bolme P, Eriksson M, Freyschuss U, et al. The effects of pharmacological treatment on pulmonary function in children with exercise-induced asthma. Acta Paediatr Scand 1980 Mar;69(2):165–72.
19. Bonini M, Lapucci G, Petrelli G, et al. Predictive value of allergy and pulmonary function tests for the diagnosis of asthma in elite athletes. Allergy 2007;62(10):1166–70.
20. Boulet LP, Turcotte H. Comparative effects of hyperosmolar saline inhalation and exercise in asthma. Immunol Allergy Pract 1989;11(3):23–30.
21. Boulet LP, Morin D, Turcotte H. Variations of airway responsiveness to methacholine and exercise in asthmatic and normal subjects over a 12-month period. Clin Invest Med 1990;13(2):60–6.
22. Bremberg SG, Kjellman NIM. Children with asthma: how do they get along at school. Acta Paediatr Scand 1985;74(6):833–40.
23. Buckley JM, Souhrada JF. A comparison of pulmonary function tests in detecting exercise induced bronchoconstriction. Pediatrics 1975;56(5 Suppl):883–9.
24. Buckley JM, Souhrada JF, Kopetzky MT. Detection of airway obstruction in exercise-induced asthma. Chest 1974;66(3):244–51.
25. Burr ML, Eldridge BA, Borysiewicz LK. Peak expiratory flow rates before and after exercise in schoolchildren. Arch Dis Child 1974;49(12):923–6.
26. Carlsen KH, Engh G, Mork M, et al. Cold air inhalation and exercise-induced bronchoconstriction in relationship to metacholine bronchial responsiveness: different patterns in asthmatic children and children with other chronic lung diseases. Respir Med 1998;92(2):308–15.
27. Carlsten C, Aitken ML, Hallstrand TS. Safety of sputum induction with hypertonic saline solution in exercise-induced bronchoconstriction. Chest 2007;131(5):1339–44.
28. Chai H, Purcell K, Brady K, et al. Therapeutic and investiational evaluation of asthmatic children. J Allergy 1968;41(1):23–36.
29. Corris PA, Nariman S, Gibson GJ. Nifedipine in the prevention of asthma induced by exercise and histamine. Am Rev Respir Dis 1983;128(6):991–2.
30. Cox AJ, Gleeson M, Pyne DB, et al. Clinical and laboratory evaluation of upper respiratory symptoms in elite athletes. Clin J Sport Med 2008;18(5):438–45.
31. Daga MK, Ahuja VM, Bajaj SK, et al. Bronchial responsiveness in normal first-degree relatives of asthmatics and patients of allergic rhinitis. JIACM 2007;8(1):36–41.
32. De Baets F, Bodart E, Dramaix-Wilmet M, et al. Exercise-induced respiratory symptoms are poor predictors of bronchoconstriction. Pediatr Pulmonol 2005;39(4):301–5.
33. Demissie K, White N, Joseph L, et al. Bayesian estimation of asthma prevalence, and comparison of exercise and questionnaire diagnostics in the absence of a gold standard. Ann Epidemiol 1998;8(3):201–8.
34. Elbiaze M, Rahimi H, El ghazi K, et al. Exercise induced asthma in schoolchildren of Fes city (Morroco) [abstract]. Allergy (Oxford) 2008;63(Suppl 88):P184.
35. Erhabor GE, Adedoyin RA, Abayomi SO, et al. Evaluation of energy expenditure using three different exercise protocols in asthmatic subjects. Fizyoterapi Rehabilitasyon 2004;15(2):55–60.
36. Evans TM, Rundell KW, Beck KC, et al. Cold air inhalation does not affect the severity of EIB after exercise or eucapnic voluntary hyperventilation. Med Sci Sports Exerc 2005;37(4):544–9.
37. Fallon K. Commentary. Br J Sports Med 2007;41(10):695.
38. Feyilola AO, Erhabor GE, Osagbenworhue OD, et al. Exercise-induced asthma in Nigerian adults: a comparison between step test, free running, and bicycle ergometer [abstract]. Chest 2007;132(4 Suppl S):508S.
39. Finnerty JP, Polosa R, Holgate ST. Repeated exposure of asthmatic airways to inhaled adenosine 5’-monophosphate attenuates bronchoconstriction provoked by exercise. J Allergy Clin Immunol 1990;86(3 Pt 1):353–9.
40. Fitch KD, Morton AR. Specificity of exercise in exercise-induced asthma. Br Med J 1971;4(5787):577–81.
41. Foucard T, Sjoberg O. A prospective 12-year follow-up study of children with wheezy bronchitis. Acta Paediatr Scand 1984;73(5):577–83.
42. Freedman S, Lane R, Gillett MK, et al. Abolition of methacholine induced bronchoconstriction by the hyperventilation of exercise or volition. Thorax 1988;43(8):631–6.
43. Frischer T, Meinert R, Urbanek R, et al. Bronchial response to exercise in a cohort of primary school children: a longitudinal study. Eur Respir J 1994;7(Suppl 18):124S.
44. Frischer T, Kuhr J, Meinert R, et al. Relation between response to exercise and diurnal variability of peak expiratory flow in primary school children. Thorax 1993;48(3):249–53.
45. Fruchter O, Yigla M. Response to bronchodilators after exercise challenge predicts bronchial hyperreactivity. J Asthma 2008;45(5):353–6.
46. Game AB, Voaklander D, Syrotuik DG, et al. Incidence of exercise-induced bronchospasm and exercise-induced hypoxaemia in female varsity hockey players. Res Sports Med 2003;11(1):11–21.
47. Gauvreau GM, Ronnen GM, Watson RM, et al. Exercise-induced bronchoconstriction does not cause eosinophilic airway inflammation or airway hyperresponsiveness in subjects with asthma. Am J Respir Crit Care Med 2000;162(4):1302–7.
48. Gerald LB, Redden D, Turner-Henson A, et al. A multi-stage asthma screening procedure for elementary school children. J Asthma 2002;39(1):29–36.
49. Godfrey S, Springer C, Noviski N, et al. Exercise but not methacholine differentiates asthma from chronic lung disease in children. Thorax 1991;46(7):488–92.
50. Golish JA. The BODE index predicted death in chronic obstructivepulmonary disease. ACP Journal Club 2004;141(2):53.
51. Granerus G, Simonsson BG, Skoogh BE, et al. Exercise-induced bronchoconstriction and histamine release. Scand J Respir Dis 1971;52(3):131–6.
52. Gruchalla RS, Gan V, Roy L, et al. Results of an innercity school-based asthma and allergy screening pilot study: a combined approach using written questionnaires and step testing. Ann Allergy Asthma Immunol 2003;90(5):491–9.
53. Gursel G, Turktas H. Air trapping as a predictor of exercise induced asthma. Eur Respir J Suppl 1996;9(23):82S.
54. Haas F, Pasierski S, Levine N, et al. Effect of aerobic training on forced expiratory airflow in exercising asthmatic humans. J Appl Physiol 1987;63(3):1230–5.
55. Haas F, Haas A. Maximum expiratory flow volume curves in the diagnosis of exercise induced broncho spasm. Physiologist 1981;24(4):29.
56. Haas F, Axen K, Pineda H, et al. Relative sensitivities of a step-wise exercise protocol and a fixed work load protocol in provoking exercise-induced bronchospasm. Am Rev Respir Dis 1982;125(4):251.
57. Hahn AG, Nogrady SG, Tumilty DM, et al. The role of histamine depletion in the refractory period after exercise-induced asthma. Aust N Z J Med 1984;14(4 Suppl 2):540–1.
58. Hamielec CM, Manning PJ, O’Byrne PM. Airway responsiveness to methacholine and histamine during the refractory period following exercise-induced asthma. Am Rev Respir Dis 1987;135(4 Pt 2):A314.
59. Hancox RJ, Subbarao P, Kamada D, et al. Beta2–agonist tolerance and exercise-induced bronchospasm. Am J Respir Crit Care Med 2002;165(8):1068–70.
60. Haugaard L, Iversen M, Dahl R. A comparative study of four different bronchial challenge tests. Allergy 1992;47(2):138–42.
61. Haverkamp H, Dempsey J, Miller J, et al. Repeat exercise normalizes the gas-exchange impairment induced by a previous exercise bout in asthmatic subjects. J Appl Physiol 2005;99(5):1843–52.
62. Heaton RW, Henderson AF, Costello JF. Cold air as a bronchial provocation technique. Reproducibility and comparison with histamine and methacholine inhalation. Chest 1984;86(6):810–4.
63. Hedlin G, Freyschuss U. Cardiac output and blood pressure in asthmatic children before and during induced asthma. Acta Paediatr Scand 1984;73(4):441–7.
64. Henriksen JM, Nielsen TT. Effect of physical training on exercise-induced bronchoconstriction. Acta Paediatr Scand 1983 Jan;72(1):31–6.
65. Higenbottam T, Stokes T, Jamieson S, et al. A comparison of exercise, hyperventilation with cold air and warm air, and the inhalation of “fog” in the provocation of asthma. Eur J Respir Dis Suppl 1983;128(Pt 2):421–3.
66. Inbar O, Alvarez D, X, Lyons HA. Exercise induced asthma: a comparison between 2 modes of exercise stress. Eur J Respir Dis 1981;62(3):160–7.
67. Inman MD, Watson RM, Killian KJ, et al. Methacholine airway responsiveness decreases during exercise in asthmatic subjects. Am Rev Respir Dis 1990;141(6):1414–7.
68. Joerres R, Boerger S, Voigt P, et al. Influence of 0.25 ppm nitrogen dioxide on exercise-induced bronchoconstriction and airway responsiveness to methacholine in asymptomatic asthmatics. Am Rev Respir Dis 1988;137(4 Pt 2):168.
69. Jones RS. Clinical value of exercise tests in childhood asthma. Thorax 1970;25(2):258.
70. Joyner BL, Fiorino EK, Matta-Arroyo E, et al. Cardiopulmonary exercise testing in children and adolescents with asthma who report symptoms of exercise-induced bronchoconstriction. J Asthma 2006;43(9):675–8.
71. Katz I, Moshe S, Levin M, et al. Does exercise cause asthma? Occup Med 2008;58(7):480–4.
72. Kiers A, Van der Mark TW, Woldring MG, et al. Changes in functional residual capacity during exercise in patients with exercise-induced asthma. Bull Eur Physiopathol Respir 1981;17(6):869–78.
73. Killian KJ, Summers E, Watson RM, et al. Factors contributing to dyspnoea during bronchoconstriction and exercise in asthmatic subjects. Eur Respir J 1993;6(7):1004–10.
74. Kinnula VL, Sovijarvi AR. Hyperventilation during exercise: independence on exercise-induced bronchoconstriction in mild asthma. Respir Med 1996;90(3):145–51.
75. Kivity S, Argaman A, Onn A, et al. Eosinophil influx into the airways in patients with exercise-induced asthma. Respir Med 2000;94(12):1200–5.
76. Kivity S, Solomon A, Schwarz Y, et al. Evaluation of asymptomatic subjects with low forced expiratory ratios (FEV1/VC). Thorax 1994;49(6):554–6.
77. Knopfli BH, Luke-Zeitoun M, Von Duvillard SP, et al. High incidence of exercise-induced bronchoconstriction in triathletes of the Swiss national team. Br J Sports Med 2007;41(8):486–91.
78. Kobayashi H, Minoguchi K, Kohno Y, et al. Exercise challenge in patients with asthma whose peak expiratory flow values are controlled within the green zone. Allergol Int 1999;48(2):145–8.
79. Kojima N, Takeda Y, Akashi M, et al. Educational asthma summer camp including exercise challenge test improved adherence [abstract]. J Allergy Clin Immunol 2007;119(1 Suppl 1):S286.
80. Koskela HO, Hyvarinen L, Brannan JD, et al. Responsiveness to three bronchial provocation tests in patients with asthma. Chest 2003;124(6):2171–7.
81. Koskela HO, Rasanen SH, Tukiainen HO. The diagnostic value of cold air hyperventilation in adults with suspected asthma. Respir Med 1997;91(8):470–8.
82. Lara M, Duan N, Sherbourne C, et al. Differences between child and parent reports of symptoms among Latino children with asthma. Pediatrics 1998;102(6):E68.
83. Lazo-Velasquez JC, Lozada AR, Cruz HM. Evaluation of severity of bronchial asthma through an exercise bronchial challenge. Pediatr Pulmonol 2005;40(5):457–63. Erratum in: Pediatr Pulmonol 2006;41(1):102.
84. Lee C, Corren J. Effects of nasal allergen challenge upon airway responsiveness to exercise [abstract]. J Allergy Clin Immunol 2008;121(2 Suppl 1):S260.
85. Lee SY, Kim HB, Kim JH, et al. Eosinophils play a major role in the severity of exercise-induced bronchoconstriction in children with asthma. Pediatr Pulmonol 2006;41(12):1161–6.
86. Magnussen H, Reuss G, Jorres R. Airway response to methacholine during exercise induced refractoriness in asthma. Thorax 1986;41(9):667–70.
87. Makker HK, Walls AF, Goulding D, et al. Airway effects of local challenge with hypertonic saline in exercise-induced asthma. Am J Respir Crit Care Med 1994;149(4):1012–9.
88. Makker HK, Holgate ST. Hypertonic saline responsiveness relates to exercise-induced asthma symptoms rather than to histamine or methacholine reactivity. Am Rev Respir Dis 1992;145(4 Pt 2):A730.
89. Makker HK, Caroll M, Gratziou C, et al. Local endobronchial hypertonic challenge in patients with exercise-induced asthma. Am Rev Respir Dis 1992;145(4 Pt 2):A729.
90. Mashalane MB, Stewart A, Feldman C, et al. Prevalence of exercise-induced bronchospasm in Thokoza school children. S Afr Med J 2006;96(1):67–70.
91. Mays W, Knecht SK, Forment YM, et al. Age specific treadmill protocol for the evaluation of exercise induced bronchospasm (EIB) in pediatric patients. Med Sci Sports Exerc 2004;36(5 Suppl S):S209–S210.
92. Mcfadden ER Jr., Stearns DR, Ingram RH Jr., et al. Relative contributions of hypocarbia and hyperpnea as mechanisms in postexercise asthma. J Appl Physiol 1977;42(1):22–7.
93. McNeill RS, Nairn JR, Millar JS, et al. Exercise-induced asthma. Q J Med 1966;35(137):55–67.
94. Mihalyka M, Wong J, James AL, et al. The effect on airway function of inspired air conditions after isocapnic hyperventilation with dry air. J Allergy Clin Immunol 1988;82(5):842–8.
95. Mildon A, Leroux M, Hutcheon M, et al. The site of airways obstruction in exercise-induced asthma. Am Rev Respir Dis 1974;110(4):409–14.
96. Mirav I, Plit M. Airway response to inhaled histamine in asthmatic children 40–60 minutes after exercise. Am Rev Respir Dis 1988;137(4 Pt 2):336.
97. Molis WE, Bagniewski S, Weaver AL, et al. Timeliness of diagnosis of asthma in children and its predictors. Allergy 2008;63(11):1529–35.
98. Morton AR, Lawrence SR, Fitch KD, et al. Duration of exercise in the provocation of exercise-induced asthma. Ann Allergy 1983;51(5):530–4.
99. Morton AR, Fitch KD, Davis T. The effect of “warm-up” on exercise-induced asthma. Ann Allergy 1979;42(4):257–60.
100. Munoz PA, Gomez FP, Manrique HA, et al. Pulmonary gas exchange response to exercise. J Appl Physiol 2008;105(5):1477–85.
101. Nagakura T, Obata T, Shichijo K, et al. GC/MS analysis of urinary excretion of 9alpha, 11beta‐PGF2 in acute and exercise-induced asthma in children. Clin Exp Allergy 1998;28(2):181–6.
102. Nichols DJ, Longsworth FG. Prevalence of exercise-induced asthma in schoolchildren in Kingston, St. Andrew and St. Catherine, Jamaica. West Indian Med J 1995;44(1):16–9.
103. Nickerson BG, Bautista DB, Namey MA, et al. Running improves fitness in asthmatic children without changing airway reactivity or ventilatory muscle function. Clin Res 1981;29(1):149A.
104. Ninan TK, Russell G. Is exercise testing useful in a community based asthma survey? Thorax 1993;48(12):1218–21.
105. Nishio K, Odajima H, Motomura C, et al. Exhaled nitric oxide and exercise-induced bronchospasm assessed by FEV1, FEF 25–75% in childhood asthma. J Asthma 2007;44(6):475–8.
106. Nowak D, Templin K, Jorres R, et al. Comparison of airway responsiveness to prostaglandin D2 and histamine, methacholine or exercise in healthy and asthmatic subjects. Ann New York Acad Sci 1991;629:442–5.
107. Nowak D, Jorres R, Magnussen H. Influence of exercise-induced bronchoconstriction on refractoriness. Lung 1992;170(2):75–84.
108. Nystad W, Stensrud T, Magnus P, et al. The association between BHR measured by metacholine and exercise challenge and their relation to atopy in school children. Eur Respir J Suppl 1997;10(25):344S.
109. Patricio L, Quarema R, Didenko I, et al. Exercise induced-asthma in high school adolescents from Setubal. Allergy (Oxford) 2007;62(Suppl 83):423–4.
110. Pedersen R. Use of exhaled nitiric oxide (eNO) as a marker for anti-inflammatory dose response of beclomethasone extrafine aerosol (Q) dosed once daily (50–100ug) in children with exercise induced asthma [abstract]. Eur Respir J 2003;(Suppl)..
111. Pedrosa M, Botello M, Caminoa M, et al. Comparative study between bronchial challenges with methacholine and adenosine in asthma diagnosis [abstract]. J Allergy Clin Immunol 2009;123(2 Suppl S):S206.
112. Pohjantahti H, Laitinen J, Parkkari J. Exercise-induced bronchospasm among healthy elite cross country skiers and non-athletic students. Scand J Med Sci Sports 2005;15(5):324–8.
113. Porsbjerg C, Rasmussen L, Thomsen SF, et al. Response to mannitol in asymptomatic subjects with airway hyper-responsiveness to methacholine. Clin Exp Allergy 2007;37(1):22–8.
114. Poswell C, V, Primhak R. Longitudinal study of free running exercise testing: is it a reproducible screening test for undiagnosed asthma? Eur Respir J 1994;7(Suppl 18):124A.
115. Potts JE. Adverse respiratory health effects of competitive swimming: the prevalence of symptoms, illnesses, and bronchial responsiveness to methacholine and exercise [dissertation]. University of British Columbia (Canada); 1994.
116. Quigley PM, Browning IB, Muelenaer AA, et al. The relationship of desaturation to exercise induced bronchospasm in a pediatric population. Am Rev Respir Dis 1989;139(4 Pt 2):A594.
117. Ragan J, King T. Exercise-induced hyperresponsiveness to methacholine: is it asthma. Am Rev Respir Dis 1988;137(4 Pt 2):510.
118. Riccioni G, D’Orazio N, Di Ilio C, et al. Bronchial hyperresponsiveness and quality of life in asthmatics. Respiration 2003;70(5):496–9.
119. Rice SG, Bierman CW, Shapiro GG, et al. Identification of exercise-induced asthma among intercollegiate athletes. Ann Allergy 1985;55(6):790–3.
120. Roecker K, Wolters R, Niess A, et al. Uncontrolled expiratory peak-flow during intensive exercise in cold air: diagnostic criterion for exercise-induced asthma? [abstract]. Med Sci Sports Exerc 2002;34(5 Suppl):S52.
121. Rosenthal RR, Laube BL, Hood DB, et al. Analysis of refractory period after exercise and eucapnic voluntary hyperventilation challenge. Am Rev Respir Dis 1990;141(2):368–72.
122. Rundell K, Im J, Wilber R, et al. Mid expiratory flow rates of cold weather athletes with exercise-induced asthma. Med Sci Sports Exerc 2001;33(5 Suppl):512.
123. Salazar-Schicchi J, Reggiani JL, Haas F, et al. Maximum expiratory flow-volume (MEFV) curves in the diagnosis of exercise-induced bronchospasm (EIB). Am Rev Respir Dis 1990;141(4 Pt 2):A221.
124. Sanchez AAS, Gerald A, Jiao Q, et al. The relationship of forced expiratory volume in one second and maximum mid-expiratory flow rate in the diagnosis of exercise induced asthma [abstract]. Chest 2005;128(4):188S.
125. Sandsund M, Reinertsen RE, Holand B, et al. Thermoregulatory and respiratory responses in asthmatic and nonasthmatic subjects breathing cold and warm air during exercise in the cold. J Therm Biol 2007;32(5):246–54.
126. Schoeffel RE, Anderson SD, Gillam I, et al. Multiple exercise and histamine challenge in asthmatic patients. Thorax 1980;35(3):164–70.
127. Schoene RB, Giboney K, Schimmel C, et al. Spirometry and airway reactivity in elite track and field athletes. Clin J Sport Med 1997;7(4):257–61.
128. Schwindt CD, Zaldivar F, Nemet D, et al. Leukocyte profiles during and after exercise challenge in asthmatic children [abstract]. Med Sci Sports Exerc 2004;36(5 Suppl S):S150.
129. Scollo M, Zanconato S, Ongaro R, et al. Exhaled nitric oxide and exercise-induced bronchoconstriction in asthmatic children. Am J Respir Crit Care Med 2000;161(3):1047–50.
130. Shin HW, Schwindt CD, Aledia AS, et al. Exercise-induced bronchoconstriction alters airway nitric oxide exchange in a pattern distinct from spirometry. Am J Physiol Regul Integr Comp Physiol 2006;291(6):R1741–8.
131. Shin Y, Lee Y, Jung Y, et al. Exercise challenge test in relation to methacholine challenge test in young asthmatics [abstract]. J Allergy Clin Immunol 2008;121(2 Suppl 1):S78.
132. Silverman M, Anderson SD. Standardization of exercise tests in asthmatic children. Arch Dis Child 1972;47(256):882–9.
133. Skadberg B, Halvorsen T, Heimdal JH, et al. Exercise induces stridor - visualising the problem [abstract]. Rev Port Cien Desp 2003;3(2):53–4.
134. Smeeton NC, Rona RJ, Oyarzun M, et al. Agreement between responses to a standardized asthma questionnaire and a questionnaire following a demonstration of asthma symptoms in adults. Am J Epidemiol 2006;163(4):384–91.
135. Smith CM, Anderson SD. Inhalational challenge using hypertonic saline in asthmatic subjects: a comparison with responses to hyperpnoea, methacholine and water. Eur Respir J 1990;3(2):144–51.
136. Soferman R, Kivity S, Marcus B, et al. Comparison between bronchial response to inhaled hypoosmolar and isoosmolar solutions of sodium cromoglycate after exercise challenge. Ann Allergy 1990;64(2 Pt 1):143–6.
137. Soifer MM, Barboriak JJ, Chyssanthopoulos C, et al. Metabolic changes in exercise-induced and methacholine-induced bronchoconstriction. J Allergy Clin Immunol 1976;57(6):576–81.
138. Song DJ, Woo CH, Kang H, et al. Applicability of interrupter resistance measurements for evaluation of exercise-induced bronchoconstriction in children. Pediatr Pulmonol 2006;41(3):228–33.
139. Spada E, Donner CF, Meriggi A, et al. The exercise broncho provocation test: 2 different procedures in treadmill running challenge. Clin Respir Physiol 1982;18(Suppl 4):233–8.
140. Stensrud T, Berntsen S, Carlsen KH. Exercise capacity and exercise-induced bronchoconstriction (EIB) in a cold environment. Respir Med 2007;101(7):1529–36.
141. Stensrud T. Maximal oxygen uptake testing, a comparison of two test protocols [abstract]. Proc Am Thorac Soc 2005;2(Abstracts Issue):B65.
142. Sudhir P, Prasad CE. Prevalence of exercise-induced bronchospasm in schoolchildren: an urban- rural comparison. J Trop Pediatr 2003;49(2):104–8.
143. Sue-Chu M, Henriksen AH, Bjermer L. Non‐invasive evaluation of lower airway inflammation in hyper-responsive elite cross-country skiers and asthmatics. Respir Med 1999;93(10):719–25.
144. Sue-Chu M, Bjermer L. Non invasive estimation of bronchial inflammation in “skiers asthma”. Eur Respir J 1997;10(Suppl 25):10S.
145. Sukanich A, Osterhus N, Fireman P. One mile run asthma screening in school children. J Allergy Clin Immunol 1999;103(1 Pt 2):S10.
146. Suzuki S, Chonan T, Sasaki H, et al. Time-course of response in exercise-induced bronchoconstriction. Ann Allergy 1984;53(4):341–6.
147. Svenonius E, Kautto R, Arborelius M Jr. Improvement after training of children with exercise-induced asthma. Acta Paediatr Scand 1983;72(1):23–30.
148. Szczeklik A, Sanak M, Nizankowska E, et al. Provocation tests in asthma: relationship between urinary cysteinyl-leukotrienes response and leukotriene C4 synthase genetic polymorphism. Eur Respir J 1998;12(Suppl 29):71S.
149. Tateishi K, Motojima S, Kushima A, et al. Comparison between allergen-induced and exercise-induced asthma with respect to the late asthmatic response, airway responsiveness, and Creola bodies in sputum. Ann Allergy Asthma Immunol 1996;77(3):229–37.
150. Taylor IK, Wellings R, Taylor GW, et al. Urinary leukotriene E4 excretion in exercise-induced asthma. J Appl Physiol 1992;73(2):743–8.
151. Wekesa M, Langhof H, Sack P. The asthma six-minute provocation test and mountain climbing in children. East Afr Med J 1994;71(1):51–4.
152. West JV, Robertson CF, Roberts R, et al. Evaluation of bronchial responsiveness to exercise in children as an objective measure of asthma in epidemiological surveys. Thorax 1996;51(6):590–5.
153. Wilson BA, Evans JN. Standardization of work intensity for evaluation of exercise-induced bronchoconstriction. Eur J Appl Physiol 1981;47(3):289–94.
154. Wrzyszcz M, Medrala W, Liebhart E, et al. Serum eosinophil cationic protein concentration in patients with exercise-induced asthma. Int Rev Allergol Clin Immunol 1996;2(3):89–92.
155. Young YK, Hyung SL, Kyung UM. Airway responsiveness to allergen is increased 24 hours after exercise challenge. J Allergy Clin Immunol 1994;94(3):507–16.
156. Zhang L, Liang YJ, Lei H, et al. Evaluation of exercise response in asthmatics: impulse oscillometry in measurement of respiratory impedance. J Clin Rehabilitative Tissue Eng Research 2007;11(31):6311–4.
157. Zielinkski J, Chodosowska E, Radomyski A. Plasma catecholamines during exercise-induced bronchoconstriction in bronchial asthma. Thorax 1980;35(11):823–7.
158. Zietkowski Z, Bodzenta-Lukaszyk A, Tomasiak MM, et al. Changes in RANTES and beta‐thromboglobulin after intensive exercise in patients with allergic asthma. Int Arch Allergy Immunol 2008;148(1):31–40

## Insufficient Data (n = 26)

1. Anderson S, Brannan J, Koskela H, et al. Inhaled mannitol: a bronchial provocation test (BPT) to identify exercise-induced bronchoconstriction (EIB). J Allergy Clin Immunol 1998;101(1 Pt 2):S117.
2. Arias IJ. Mild to moderate asthmatics and free running. J Investig Allergol Clin Immunol 1999;9(1):50–4.
3. Boner AL, Sette L, Piacentini G, et al. Exercise-induced biphasic responses and methacholine reactivity in asthma. Ann Allergy 1990;65(4):284–6.
4. Brown LL, Martin BL, Morris MJ. Airway hyperresponsiveness by methacholine challenge testing following negative exercise challenge. J Asthma 2004;41(5):553–8.
5. Brown LL, Martin BL, Morris MJ. Airway hyperresponsiveness in methacholine challenge following negative exercise challenge. J Allergy Clin Immunol 2001;107(2):S303.
6. Charpin-Kadouch C, Ercoli J, Quralt J, et al. Is spirometry a better tool than measurement of peak flow for monitoring a rub-test for screening exercise-induced asthma? J Allergy Clin Immunol 2007;119(1 Suppl 1):S89.
7. Chmelik F. The degree of exercised induced asthma EIA comparing eucapnic voluntary hyperventilation EVH vs treadmill exercise TM. Ann Allergy 1990;64:82.
8. Dor A. Comparison of exercise and histamine provocation tests in patients with bronchial asthma. Pneumonol Alergol Pol 2009;67(1–2):22–7.
9. Eggleston PA. The cycloergometer as a system for studying exercise-induced asthma. Pediatrics 1975;56(5 Pt 2 Suppl):899–903.
10. Evans TM, Rundell KW, Beck KC, et al. Impulse oscillometry is sensitive to bronchoconstriction after eucapnic voluntary hyperventilation or exercise. J Asthma 2006;43(1):49–55.
11. Horie T, Enomoto S, Inazawa T, et al. Bronchial hyper sensitivity in exercise induced asthma. Jpn J Med 1982;21(4):317.
12. Kivity S, Souhrada JF. Hyperpnea: the common stimulus for bronchospasm in asthma during exercise and voluntary isocapnic hyperpnea. Respiration 1980;40(4):169–77.
13. Koh YI, Choi S. Blood eosinophil counts for the prediction of the severity of exercise-induced bronchospasm in asthma. Respir Med 2002;96(2):120–5.
14. Lara ME, Sherbourne C, Halfon N, et al. Evaluating exercise induced symptoms in children with asthma: should we ask parents, children, or do peak flows? J Invest Med 1996;44(1):156A.
15. Martin-Vivaldi F, Fernandez E, Moreno R, et al. A comparison of two treadmill exercise tests for the diagnosis of exercise induced bronchospasm (EIB). Eur Respir J 1994;7(Suppl 18):326S.
16. Novey HS, Wilson AF, Surprenant EL, et al. Early ventilation-perfusion changes in asthma. J Allergy 1970;46(4):221–30.
17. Panditi S, Silverman M. Perception of exercise induced asthma by children and their parents. Arch Dis Child 2003;88(9):807–11.
18. Pedersen L, Lund TK, Barnes PJ, et al. Airway responsiveness and inflammation in adolescent elite swimmers. J Allergy Clin Immunol 2008;122(2):322–7.
19. Pierson WE, Shapiro GG, Furukawa CT, et al. Methacholine sensitivity in allergic patients with and without exercise-induced bronchospasm. J Allergy Clin Immunol 1980;65(3):207.
20. Rosenthal RR, Laube B, Jaeger JJ, et al. Methacholine sensitivity is unchanged during the refractory period following an exercise or isocapnic challenge. J Allergy Clin Immunol 1984;73(1 Pt 2):179.
21. Rupp NT, Guill MF, Brudno DS, et al. The value of screening for risk of exercised induced asthma in high school athletes. J Allergy Clin Immunol 1991;87(1 Pt 2):165.
22. Seear M, Wensley D, West N. How accurate is the diagnosis of exercise induced asthma among Vancouver schoolchildren?. Arch Dis Child 2005;90(9):898–902.
23. Shapiro GG, Pierson WE, Furukawa CT, et al. A comparison of the effectiveness of free-running and treadmill exercise for assessing exercise-induced bronchospasm in clinical practice. J Allergy Clin Immunol 1979;64(6 Pt 2):609–11.
24. Shield S, Wang-Dohlman A. Incidence of exercise-induced bronchospasm (EIB) in high school football players. J Allergy Clin Immunol 1991;87(1 Pt 2):166.
25. Vecchio C, Donner CF, Ioli F, et al. Comparative study between free-running and a new treadmill running procedure in exercise bronchoprovocation challenge. Respiration 1984;46(Suppl 1):65.
26. Wiens L, Sabath R, Scagliotti D, et al. The frequency of exercise-induced asthma presenting as chest pain in children. J Allergy Clin Immunol 1991;87(1 Pt 2):295.

## Other Diagnostic Tests (n = 24)

1. Bar-Yishay E, Gur I, Inbar O, et al. Differences between swimming and running as stimuli for exercise-induced asthma. Eur J Appl Physiol 1982;48(3):387–97.
2. Buchvald F, Hermansen MN, Nielsen KG, et al. Exhaled nitric oxide predicts exercise-induced bronchoconstriction in asthmatic school children. Chest 2005;128(4):1964–7.
3. ElHalawani SM, Ly NT, Mahon RT, et al. Exhaled nitric oxide as a predictor of exercise-induced bronchoconstriction. Chest 2003;124(2):639–43.
4. Feinstein RA, LaRussa J, Wang-Dohlman A, et al. Screening adolescent athletes for exercise-induced asthma. Clin J Sport Med 1996;6(2):119–23.
5. Holzer K, Anderson SD, Douglass J. Exercise in elite summer athletes: Challenges for diagnosis. J Allergy Clin Immunol 2002;110(3):374–80.
6. Holzer K, Anderson SD, Chan HK, et al. Mannitol as a challenge test to identify exercise-induced bronchoconstriction in elite athletes. Am J Respir Crit Care Med 2003;167(4):534–7.
7. Holzer K, Anderson S, Douglass J. Methacholine has a low sensitivity to identify elite athletes with a positive response to eucapnic voluntary hyperpnea. Med Sci Sports Exerc 2002;34(5 Suppl).
8. Horie T, Enomoto S, Inazawa T, et al. Comparison of airway responsiveness to exercise and histamine inhalation in asthmatics. Jpn J Med 1983;22(1):26–30.
9. Hurwitz KM, Roach JM, Argyros GJ, et al. Refractory period during provocation with eucapnic hyperventilation and methacholine. Am J Respir Crit Care Med 1994;149(6):1452–6.
10. Inbar O, Dotan R, Dlin RA, et al. Breathing dry or humid air and exercise-induced asthma during swimming. Eur J Appl Physiol 1980;44(1):43–50.
11. Kilham H, Tooley M, Silverman M. Running, walking, and hyperventilation causing asthma in children. Thorax 1979;34(5):582–6.
12. LaRussa J, Feinstein R, Wang-Dohlman A. A simple exercise test to identify exercise induced bronchospasm in adolescent athletes. Clin Res 1992;40(4):775A.
13. Manning PJ, Watson RM, O’Byrne PM. Exercise-induced refractoriness in asthmatic subjects involves leukotriene and prostaglandin interdependent mechanisms. Am Rev Respir Dis 1993;148(4):950–4.
14. Mellis CM, Kattan M, Keens TG, et al. Comparative study of histamine and exercise challenges in asthmatic children. Am Rev Respir Dis 1978;117(5):911–5.
15. Patricio L, Didenko I, Campos L, et al. Detecting exercise-induced asthma using adenosine 5 ‘‐ monophosphate or methacholine challenges [abstract]. Allergy (Oxford) 2008;63(Suppl 88):285.
16. Soferman R, Spirer Z, Topilsky M. Small airway responsiveness to exercise as an objective measure of exercise-induced asthma in children. Pediatr Asthma Allergy Immunol 2003;16(2):77–84.
17. Strauss RH, Haynes RL, Ingram RH Jr., et al. Comparison of arm versus leg work in induction of acute episodes of asthma. J Appl Physiol 1977;42(4):565–70.
18. Sylvester KP, O’Connor BJ, Farebrother HM, et al. Cold air and exercise challenge — influence of minute ventilation. J Asthma 2007;44(2):143–7.
19. Tancredi G, Quattrucci S, Scalercio F, et al. 3-min step test and treadmill exercise for evaluating exercise-induced asthma. Eur Respir J 2004;23(4):569–74.
20. Tweeddale PM, Godden DJ, Grant IW. Hyperventilation of exercise to induce asthma? Thorax 1981;36(8):596–8.
21. Van Den ELSH, Van HC, Molema J, et al. Exercise-induced bronchoconstriction (EIB) detected with the forced oscillation technique. Am Rev Respir Dis 1990;141(4 Pt 2):A834.
22. Webner D, Disabella V. Exercise-induced asthma (EIA): a diagnosis of inclusion? [abstract]. Clin J Sport Med 2005;15(4):281.
23. Young RP, Holst PE. A simple exercise test in assessment of asthma. New Zealand Med J 1988;101(854):600–1.
24. Zeballos RJ, Shturman-Ellstein R, McNally JF Jr., et al. The role of hyperventilation in exercise-induced bronchoconstriction. Am Rev Respir Dis 1978;118(5):877–84. .

## Duplicate Publication (n = 2)

1. Kiviloog J. The correlation between exercise induced bronchoconstriction and bronchial methacholine sensitivity in asthma. Pediatrics 1975;56(5 Suppl):908–9.
2. Kiviloog J. Variability of bronchial reactivity to exercise and metacholine in bronchial asthma. Scand J Respir Dis 1973;54(6):359–68.

## Language (n = 1)

1. Varray A, Mercier J, Ramonatxo M, et al. L’exercise physique maximal chez l’enfant asthmatique: limitation aerobie et compensation anaerobie? Science & Sports 1989;4(3):199–207. French.

## Unable to Retrieve (n = 10)

1. Ames J. Exercise induced bronchospasm. Sports Med Clinic Newsletter 1986;1–2.
2. Garfinkel SK, Kesten S, Chapman KR, Rebuck AS. Physiologic and nonphysiologic determinants of aerobic fitness in mild to moderate asthma. Am Rev Respir Dis 1992;145(4:Pt 1):741–5. Erratum in: Am Rev Respir Dis 1992;146(1):269.
3. Hay JM. Exercise induced asthma & the athlete. Sports Physical Therapy Section 1999;3.
4. Hoher K. Prevalence of exercise-induced bronchoconstriction (eib) in young athletes identified by eucapnic voluntary hyperpnea (evh). Respirology 2001;6(Suppl 1):A10.
5. Irnell L, Kiviloog J, Strom G. Variation of maximal expiratory flow at exercise test in patients with bronchial asthma. Bronches 1968;18(6):506–9.
6. Laitinen LA. Histamine and metacholine challenge in the testing of bronchial reactivity. Scand J Respir Dis Suppl 1974;86:1–48.
7. Mcfadden ER Jr. Exercise performance in the asthmatic. Am Rev Respir Dis 1984;129(2 Pt 2):S84–7.
8. Roksund OD, Nja F, Svidal B, Carlsen KH. Sensitivity and specificity of a standard exercise challenge test in asthmatic and healthy school children. Am J Respir Crit Care Med 1999;159(3):A673.
9. Tower J. Office testing for exercise-induced asthma. Alaska Med 1978;20(5):70–1.
10. Zohar O. Exercise induced asthma. Aust J Physiother 1996;42(1):3–5.

## Therapy for EIB/EIA review

368 studies were excluded from the review. Reasons for exclusion include: study design (n=60), population (n=32), intervention (n=214), no comparison (n=2), outcome (n=1), language (n=38), insufficient data (n=12), and duplicate publication (n=9). We were not able to retrieve the reports of 15 studies.

## Study Design (n = 60)

1. Levalbuterol for asthma. Med Lett Drugs Ther 1999;41(1054):51–3.
2. Allegra J, Field J, Trautlein J, et al. Oral terbutaline sulfate—amelioration of exercise-induced bronchospasm. J Clin Pharmacol 1976;16(7):367– 70.
3. Anderson S, Rodwell L, Toit J, YoungI. Salmeterol, a novel beta-adrenoceptor agonist, provides longer protection against exercise-induced asthma EIA compared with salbutamol. Aust N Z J Med 1991;21:644.
4. Anderson SD, Bye PT, Schoeffel RE, et al. Arterial plasma histamine levels at rest, and during and after exercise in patients with asthma: effects of terbutaline aerosol. Thorax 1981;36(4):259–67.
5. Atkinson DC, Torres M. Comparison of two bronchodilator inhalers in adolescents and adults with exercise-induced asthma. [Internet] 2004 Jun. [cited 2009 Aug 31]. Available from: http://clinicaltrials.gov/ct2/show/NCT00085774
6. Bierman CW, Shapiro GG, Furukawa CT, et al. Double-blind cross-over study of theophylline and terbutaline in exercise-induced bronchospasm. J Allergy Clin Immunol 1979;63(3):No. 75.
7. Boner AL, Niero E, Grigolini C, et al. Inhibition of exercise-induced asthma by three forms of sodium cromoglycate. Eur J Respir Dis 1985;66(1):21–4.
8. Bundgaard A. Exercise-induced asthma - laboratory observations. Eur J Respir Dis Suppl 1983;128(Pt 1):253–7.
9. Bundgaard A. Pretreatment of exercise-induced asthma with beta-2 agonists inhaled from RV to TLC or at TLC. A preliminary report. Eur J Respir Dis Suppl 1983;128(Pt 2):518–20.
10. Cavallo A, Cassaniti C, Glogger A, Magrini H. Action of nedocromil sodium in exercise-induced asthma in adolescents. J Investig Allergol Clin Immunol 1995;5:286–8.
11. Ceugniet F, Cauchefer F, Fragneaud C, Evano-Celli I. Prophylactic treatment of exercise-induced asthma in children: salmeterol or sodium cromoglycate single dose before exercise? Ann Pediatr (Paris) 1997;44(9):625–34.
12. Chung JT, Jones RS. Bronchodilator effect of sodium cromoglycate and its clinical implications. Br Med J 1979;2(6197):1033–4.
13. Comerford M. The use of nedocromil sodium in the prevention of exercise-induced bronchoconstriction. Pediatr Nurs 2000;26(5):523–5.
14. D’Alonzo GE. Efficacy of inhaled salmeterol in the treatment of asthma. Eur Respir Rev 1995;5(27):128–32.
15. Davies SE. Effect of disodium cromoglycate on exercise-induced asthma. Br Med J 1968;3(618):593–4.
16. De Benedictis FM, Tuteri G, Alunni F, et al. Combination drug therapy for the prevention of exercise-induced asthma in children [abstract]. Eur Respir J Suppl 1995;8(Suppl 19):518S.
17. Ferres J, Guasch E, Garcia MP, Julia A. Assessing the efficacy of nedocromil sodium in exercise induced asthma [abstract]. Eur Respir J Suppl 1990;3(Suppl 10):385S.
18. Ferres J, Recoder O, Ferres RM, et al. Formoterol in the prevention of exercise induced asthma in children five hours before a free running test [abstract]. Eur Respir J Suppl 1996;9(Suppl 23):286S.
19. Ferres J, Recoder O, Andrew MA, et al. Prevention of exercise induced asthma by prior administration of sodium nedocromil with spacer [abstract]. Eur Respir J Suppl 1993;6 (Suppl 17):355S.
20. Gaile S, Philip G, Pearlman DS, et al. Reduction of the severity and duration of exercise-induced bronchoconstriction by single-dose montelukast or salmeterol [abstract]. American Thoracic Society International Conference, May 18–23, 2007, San Francisco, California, USA.
21. Higgs CM, Laszlo G. The duration of protection from exercise-induced asthma by inhaled salbutamol, and a comparison with inhaled reproterol. Br J Dis Chest 1983;77(3):262–9.
22. Holmes TH, Morgan BA, Wollf CR. The effect of disodium cromoglycate on plasma 17‐hydroxycorticoid concentration during exercise. Am Rev Respir Dis 1972;106(4):610–3.
23. Ienna TM, McKenzie DC. The asthmatic athlete: metabolic and ventilatory responses to exercise with and without pre-exercise medication. Int J Sports Med 1997;18(2):142–8.
24. Knopfli BH, Bar-Or O, Araujo CG. Effect of ipratropium bromide on EIB in children depends on vagal activity. Med Sci Sports Exerc 2005;37(3):354–9.
25. Konig P, Jaffe P, Godfrey S. Effect of corticosteroids on exercise-induced asthma. J Allergy Clin Immunol 1974;54(1):14–9.
26. Lenney W, Milner AD, Tyler RM. BRL10833 in inhibiting exercise-induced bronchoconstriction in asthmatic children. Br J Dis Chest 1978;72(3):225–30.
27. Lund T. Elite sport and development of asthma. [Internet] 2005 Dec. [Cited 2009 Aug 31]. Available from: http://clinicaltrials.gov/ct2/show/NCT00262587
28. Markham A, Faulds D. Montelukast. Drugs 1998;56(2):251–6.
29. McCarthy OR. The prevention of exercise induced asthma. Br J Dis Chest 1972;66(2):133–40.
30. McNeill RS, Nairn JR, Millar JS, Ingram CG. Exercise-induced asthma. Q J Med 1966;35(137):55–67.
31. Melo RE, Sole D, Naspitz CK. Comparative efficacy of inhaled furosemide and disodium cromoglycate in the treatment of exercise-induced asthma in children. J Allergy Clin Immunol 1997;99(2):204–9.
32. Melo RE, Sole D, Naspitz CK. Exercise-induced bronchoconstriction in children: montelukast attenuates the immediate-phase and late-phase responses. J Allergy Clin Immunol 2003;111(2):301–7.
33. Merck. An approved drug to study a new indication in exercise-induced bronchospasm. [Internet] 2004 Aug. [Cited 2009 Aug 31]. Available from: http://clinicaltrials.gov/ct2/show/NCT00090142
34. Merck. An investigational drug to prevent exercise-induced bronchospasm. [Internet] 2005 Oct. [Cited 2009 Aug 31]. Available from: http://www.clinicaltrials.gov/ct2/show/NCT00245570
35. Mihalyka MS, Anderson SD, Corte P. Nedocromil sodium in exercise-induced asthma EIA [abstract]. Aust N Z J Med 1987;17(Suppl 12):524.
36. Muijsers RBR, Noble S. Montelukast: a review of its therapeutic potential in asthma in children 2 to 14 years of age. Paediatr Drugs 2002;4(2):123–39.
37. Nathan RA, Dorinsky P, Rosenzweig JRC, et al. Improved ability to perform strenuous activities after treatment with fluticasone propionate/salmeterol combination in patients with persistent asthma. J Asthma 2003;40(7):815–822.
38. Nsouli SM. Efficacy of montelukast, a leukotriene receptor antagonist for the treatment of exercise induced bronchoconstriction. Ann Allergy Asthma Immunol 1999;82:100.
39. Patel KR, Kerr JW. The dose-duration effect of sodium cromoglycate in exercise-induced asthma. Clin Allergy 1984;14(1):87–91.
40. Peroni DG, Piacentini GL, Loiacono A, et al. Efficacy of single-dose montelukast on exercise-induced bronchoconstriction in children. Eur Respir J 2001;18(Suppl 33):495S.
41. Philip G, Pearlman DS, Villaran C, et al. Protection against exercise-induced bronchoconstriction by single-dose montelukast or salmeterol [abstract]. American Thoracic Society International Conference, May 18–23, 2007, San Francisco, California, USA.
42. Philip G, van Adelsberg J, Pearlman DS, et al. Randomized, placebo-controlled studies of onset and duration of single-dose protection against exercise-induced bronchoconstriction [abstract]. Eur Respir J 2005;26(Suppl 49):Abstract 1730.
43. Pichaipat V, Tongpenyai Y, Nerntong T, Sriprapachiranont C. The protective effect of inhaled terbutaline, sodium cromoglycate and budesonide on exercise-induced asthma in children. J Med Assoc Thai 1995;78(10):505–8.
44. Poppius H, Muittari A, Kreus KE, et al. Exercise asthma and disodium cromoglycate. Br Med J 1970;4(731):337–9.
45. Rebic P, Petrovic V, Savic J, et al. Protective effect of fenoterol, cromolyn, and their combination on exercise-induced asthma: comparison between young and adult patients [abstract]. Eur Respir J Suppl 1994;7(Suppl 18):112s.
46. Ringel KP, El Nur AR, Karg F. FPL 52758 and disodium cromoglycate (INTAL) in exercise-induced infantile bronchoconstriction. Z Erkr Atmungsorgane 1982;159(1):50–6.
47. Rohr AS, Siegel SC, Katz RM, et al. A comparison of inhaled albuterol and cromolyn in the prophylaxis of exercise-induced bronchospasm. Ann Allergy 1987;59(2):107–9.
48. Russo GH, Bellia CA, Bodas AW. Exercise-induced asthma (EIA): its prevention with the combined use of ipratropium bromide and fenoterol. Respiration 1986;50(Suppl 2):258–61.
49. Scherrer M, Gmur H. Protection against exercise-induced asthma. Allergologie 1981;4(1):46–7.
50. Selcow JE. Cromolyn therapy in children. J Asthma 1983;20(5):361–8.
51. Silverman M, Tooley M. Oxatomide and exercise-induced asthma in children: the value of serial exercise tests. Clin Allergy 1981;11(5):421–8.
52. Steinshamn S, Sandsund M, Sue-Chu M, Bjermer L. Effects of montelukast on cardiopulmonary ergonomy and physical performance during exercise in adult asthmatics with exercise-induced bronchoconstruction. Am J Respir Crit Care Med 2001;163(5 Suppl):429.
53. Stemmann EA, Kosche F. A comparison of the effects of Sch 1000 MDI, sodium cromoglycate and beta-adrenergic drugs on exercise-induced asthma in children. Postgrad Med J 1975;51 S:105–6.
54. Svenonius E, Arborelius M Jr., Wiberg R, Ekberg P. Prevention of exercise-induced asthma by drugs inhaled from metered aerosols. Allergy 1988;43(4):252–7.
55. Vidal C, Fernandez OE, Eiro J, et al. Comparison of montelukast versus budesonide in the treatment of exercise-induced bronchoconstriction. Ann Allergy Asthma Immunol 2001;86(6):655–8.
56. Waalkens HJ, van Essen Zandvliet EE, Gerritsen J, et al. The effect of an inhaled corticosteroid budesonide on exercise-induced asthma in children. Dutch CNSLD Study Group. Eur Respir J 1993;6(5):652–6.
57. Wallace D, Grieco MH. Double-blind, cross-over study of cromolyn sodium inhibition of exercise-induced bronchospasm in adults. Ann Allergy 1976;37(3):153–63.
58. Warner JO. The role of leukotriene receptor antagonists in the treatment of chronic asthma in childhood. Allergy 2001;56:22–9.
59. Woolley MJ. The duration of action of terbutaline and sodium cromoglycate alone and in combination on exercise-induced asthma EIA [abstract]. Aust N Z J Med 1988;18(3 Suppl 2):538.
60. Yergen U, Till D, Ziehmer B, Kottakis J. Formeterol (foradil, aerolizer) protects against exercise induced bronchoconstriction [abstract]. J Allergy Clin Immunol 2003;111(2 Suppl):S144.

## Population (n = 32)

1. Albazzaz MK, Neale MG, Patel KR. Dose-response study of nebulised nedocromil sodium in exercise induced asthma. Thorax 1989;44(10):816–9.
2. Albazzaz MK, Neale MG, Patel KR. Dose duration of nebulized nedocromil sodium in exercise-induced asthma. Eur Respir J 1992;5(8):967–9.
3. Bigby B, Boushey H. Effects of nedocromil sodium on the bronchomotor response to sulfur dioxide in asthmatic patients. J Allergy Clin Immunol 1993;92(1 Pt 2):195–7.
4. Butz AM. Nebulizer intervention for minority children with asthma. [Internet] 2005 Sept. [Cited 2009 Aug 31]. Available from: http://clinicaltrials.gov/ct2/show/NCT00218816
5. Ceylan E, Mehmet G, Sahin A. Addition of formoterol or montelukast to low-dose budesonide: an efficacy comparison in short- and long-term asthma control. Respiration 2004;71(6):594–601.
6. Dahlen B, Margolskee DJ, Zetterstrom O, Dahlen SE. Effect of the leukotriene receptor antagonist MK-0679 on baseline pulmonary function in aspirin sensitive asthmatic subjects. Thorax 1993;48(12):1205–10.
7. Freeman W, Packe GE, Cayton RM. Effect of nebulised salbutamol on maximal exercise performance in men with mild asthma. Thorax 1989;44(11):942–7.
8. Freeman W, Javaid A, Cayton RM. Ipratropium bromide and maximum exercise performance in asthmatic subjects [abstract]. Eur Respir J Suppl 1990;3(Suppl 10):439S.
9. GlaxoSmithKline. A study measuring asthma control in pediatric and adolescent subjects whose asthma is worsened by activity or exercise. [Internet] clinicaltrials gov 2006.
10. Hansel TT, Benezet O, Kafe H, et al. A multinational, 12-week, randomized study comparing the efficacy and tolerability of ciclesonide and budesonide in patients with asthma. Clin Ther 2006;28(6):906–20.
11. Jokic R, Swystun VA, Davis BE, Cockcroft DW. Regular inhaled salbutamol: effect on airway responsiveness to methacholine and adenosine 5’‐monophosphate and tolerance to bronchoprotection. Chest 2001;119(2):370–5.
12. Kreisman H, Frank H, and GM. The effect of ipratropium on exercise-induced asthma [abstract]. J Allergy Clin Immunol 1979;63(3):153.
13. Langton HS, Hobbs J, Connett G, Lenney W. Salmeterol in the prevention of exercise-induced bronchospasm in preschool children. Eur Respir J Suppl 1994;7(Suppl 18):451S.
14. Leech S, Wolfson K, Burns R. Ketotifen vs. disodium cromoglycate DSCG in the prophylaxis of exercise-induced asthma EIA. Ann Allergy 1983;50:352.
15. Maesen FP, Nakratzas G, Bantje TA, et al. Formoterol suspension aerosol. Comparison with formoterol solution aerosol for 12 weeks in asthmatic patients. Chest 1992;102(5):1544–9.
16. Magnussen H, Nowak D, Wiebicke W. Effect of inhaled ipratropium bromide on the airway response to methacholine, histamine, and exercise in patients with mild bronchial asthma. Respiration 1992;59(1):42–7.
17. McAlpine LG, Thomson NC. Prophylaxis of exercise-induced asthma with inhaled formoterol, a long-acting beta 2-adrenergic agonist. Respir Med 1990;84(4):293–5.
18. Molema J, van Herwaarden CL, Folgering HT. Effects of long-term treatment with inhaled cromoglycate and budesonide on bronchial hyperresponsiveness in patients with allergic asthma. Eur Respir J 1989;2(4):308–16.
19. Morton AR, Turner KJ, Fitch KD. Protection from exercise-induced asthma by pre-exercise cromolyn sodium and its relationship to serum IGE levels. Ann Allergy 1973;31(6):265–71.
20. Nelson H, Kemp JP, Bieler S, et al. Comparative efficacy and safety of albuterol sulfate spiros inhaler and albuterol metered-dose inhaler in asthma. Chest 1999;115(2):329–35.
21. Noonan M, Corren J, Leflein J. Safety of mometasone furoate dry powder inhaler and comparison with beclomethasone dipropionate in children with asthma previously maintained on inhaled corticosteroids (ICS) [abstract]. Chest 2004;126(4 Suppl):912S.
22. Patel KR. Bronchodilator activity of a new inhaled betasub 2-adrenoceptor agonist, tulobuterol and its protective effect in exercise-induced asthma. Br J Clin Pharmacol 1986;21(2):234–7.
23. Pfleger A, Eber E, Weinhandl E, Zach MS. Effects of nedocromil and salbutamol on airway reactivity in children with asthma. Eur Respir J 2002;20(3):624–9.
24. Raissy HH. Exercise induced bronchospasm in children. [Internet] 2006 Jan. [Cited: 2009 Aug 31]. Available from: http://clinicaltrials.gov/ct2/show/NCT00273689
25. Rundell KW, Spiering BA, Baumann JM, Evans TM. Bronchoconstriction provoked by exercise in a high-particulate-matter environment is attenuated by montelukast. Inhal Toxicol 2005;17(2):99–105.
26. Sanguinetti CM, Gasparini S, Bonifazi F, Vennarucci LS. Exercise-induced asthma diagnosis and prevention with a metered dose aerosol formulation of sodium cromoglycate. Respiration 1982;43(2):132–41.
27. Silverman M, Andrea T. Time course of effect of disodium cromoglycate on exercise-induced asthma. Arch Dis Child 1972;47(253):419–22.
28. Speelberg B, Verhoeff NP, van den Berg NJ, et al. Nedocromil sodium inhibits the early and late asthmatic response to exercise. Eur Respir J 1992;5(4):430–7.
29. Sue-Chu M, Sandsund M, Helgerud J, et al. Salmeterol and physical performance at -15 degrees C in highly trained nonasthmatic cross-country skiers. Scand J Med Sci Sports 1999;9(1):48–52.
30. Telenga ED, Kerstjens HA. Effect of inhaled hyaluronic acid (HA) on exercised induced bronchoconstriction (EIB). Pulm Pharmacol Ther 2008;21(2):430.
31. Unnithan VB, Thomson KJ, Aitchison TC, Paton JY. Beta 2-agonists and running economy in prepubertal boys. Pediatr Pulmonol 1994;17(6):378–82.
32. von Berg A, Berdel D. Efficacy of formoterol metered aerosol in children. Lung 1990;168(Suppl l):90–8.

## Intervention (n = 214)

1. Adelman A. Montelukast for mild and exercise-induced asthma. J Fam Pract 1998;47(5):335.
2. Adelroth E, Inman MD, Summers E, et al. Prolonged protection against exercise-induced bronchoconstriction by the leukotriene D4-receptor antagonist cinalukast. J Allergy Clin Immunol 1997;99(2):210–5.
3. Allegra J, Field J, Trautlein J, et al. The pharmacologic effect of aerosolized terbutaline sulfate in exercise-induced bronchospasm. J Clin Pharmacol 1976;16(8–9):444–7.
4. Alvarez D, Rodriguez V, Fernandez S, et al. Comparison of the protective effect on exercise induced brochospasm between albuterol and albuterol+ipratropium bromide in pediatric asthma patients [abstract]. Am J Respir Crit Care Med 2002;165(8 Suppl):A740.
5. Alvarez J, Rosales M, Sanchez LC, et al. Effect of nedocromil sodium compared to budesonide as prevention of bronchospasm induced by exercise test and methacoline test in asthma patients. Eur Respir J Suppl 1996;9 Suppl 23:34S.
6. Anderson SD, Rozea PJ, Dolton R, et al. Inhaled and oral bronchodilator therapy in exercise induced asthma. Aust N Z J Med 1975;5(6):544–50.
7. Anderson SD, Lambert S, Brannan JD, et al. Laboratory protocol for exercise asthma to evaluate salbutamol given by two devices. Med Sci Sports Exerc 2001;33(6):893–900.
8. Becker A, Kumar R, Stewart L, et al. Chronobiology of exercise-induced bronchconstriction (EIB) in pediatric asthma: response to montelukast [abstract]. Am J Respir Crit Care Med 2000;161(3 Suppl):A194.
9. Belcher NG, Rees PJ, Clark TJ, et al. A comparison of the refractory periods induced by hypertonic airway challenge and exercise in bronchial asthma. Am Rev Respir Dis 1987;135(4):822–5.
10. Ben D, I, Gur I, Bar YE, et al. Refractory period following induced asthma: contributions of exercise and isocapnic hyperventilation. Thorax 1983;38(11):849–53.
11. Berkowitz R, Schwartz E, Bukstein D, et al. Albuterol protects against exercise-induced asthma longer than metaproterenol sulfate. Pediatrics 1986;77(2):173–8.
12. Blake K, Pearlman DS, Scott C, et al. Prevention of exercise-induced bronchospasm in pediatric asthma patients: a comparison of salmeterol powder with albuterol. Ann Allergy Asthma Immunol 1999;82(2):205–11.
13. Boner AL, Vallone G, Brighenti C, et al. Comparison of the protective effect and duration of action of orally administered clenbuterol and salbutamol on exercise-induced asthma in children. Pediatr Pulmonol 1988;4(4):197–200.
14. Boner AL, Spezia E, Piovesan P, et al. Inhaled formoterol in the prevention of exercise-induced bronchoconstriction in asthmatic children. Am J Respir Crit Care Med 1994;149(4 Pt 1):935–9.
15. Bonsignore MR, La Grutta S, Cibella F, et al. Effects of exercise training and montelukast in children with mild asthma. Med Sci Sports Exerc 2008;40(3):405–12.
16. Brannan JD, Anderson SD, Freed R, et al. Nedocromil sodium inhibits responsiveness to inhaled mannitol in asthmatic subjects. Am J Respir Crit Care Med 2000;161(6):2096–9.
17. Brodde OE, Petrasch S, Bauch HJ, et al. Terbutaline-induced desensitization of beta 2‐adrenoceptor in vivo function in humans: attenuation by ketotifen. J Cardiovasc Pharmacol 1992;20(3):434–9.
18. Bronsky EA, Spector SL, Pearlman DS, et al. Albuterol aerosol versus albuterol Rotacaps in exercise-induced bronchospasm in children. J Asthma 1995;32(3):207–14.
19. Bronsky EA, Kemp JP, Zhang J, et al. Dose-related protection of exercise bronchoconstriction by montelukast, a cysteinyl leukotriene-receptor antagonist, at the end of a once-daily dosing interval. Clin Pharmacol Ther 1997;62(5):556–61.
20. Bronsky EA, Yegen U, Yeh CM, et al. Formoterol provides long-lasting protection against exercise-induced bronchospasm. Ann Allergy Asthma Immunol 2002;89(4):407–12.
21. Bronsky EA, Pearlman DS, Pobiner BF, et al. Prevention of exercise-induced bronchospasm in pediatric asthma patients: a comparison of two salmeterol powder delivery devices. Pediatrics 1999;104(3 Pt 1):501–6.
22. Bronsky F, Yegen U, Yeh CM, et al. Foradil provides rapid and long acting protection against exercise-induced bronchospasm [abstract]. Ann Allergy Asthma Immunol 1998;80:129.
23. Bundgaard A, Ingemann-Hansen T, Halkjaer-Kristensen J, et al. Short-term physical training in bronchial asthma. Br J Dis Chest 1983;77(2):147–52.
24. Busse WW, Dahiya GG, Yancey SW. Single doses of salmeterol provide protection against exercise-induced bronchospasm (EIB) for 12 hours. Ann Allergy 1994;72:95.
25. Capristo AF, del Giudice MM, Maiello N, et al. Montelukast for the treatment of exercise induced asthma in children, mid term study. Eur Respir J Suppl 1999;14(Suppl 30):362.
26. Carlsen KH, Roksund O, Olsholt K, et al. Overnight protection by inhaled salmeterol on exercise- induced asthma in children. Eur Respir J 1995;8(11):1852–5.
27. Cavagni G, Caffarelli C, Manni PL, et al. Salbutamol administered through a new spacer device to prevent exercise-induced asthma. Adv Ther 1993;10(5):207–16.
28. Cavagni G, Monici Preti PA, Caffarelli C, et al. Salbutamol administered via a new spacer device in preventing exercise-induced asthma [abstract]. Eur Respir J Suppl 1993;6(Suppl 17):353S.
29. Clark RA, Reid PC, Taak NK. A comparison of the duration of protection against exercise induced bronchoconstriction following single and chronic dosing with salmeterol and sodium cromoglycate in children [abstract]. Eur Respir J Suppl 1995;8(Suppl 19):517S.
30. Colice GL, Klinger NM, Ekholm BP, et al. Proventil HFA prevents exercise-induced bronchoconstriction in children. J Asthma 1999;36(8):671–6.
31. Corren J, Firriolo K, Ghannam A, et al. The effect of add-on therapy with montelukast or salmeterol on exercise-associated asthma exacerbation and recovery following rescue short-acting beta-agonist. Annual Thoracic Society 97th International Conference; San Francisco CA, May 18–23 2001.
32. Dahlen B, Roquet A, Inman MD, et al. Influence of zafirlukast and loratadine on exercise-induced bronchoconstriction. J Allergy Clin Immunol 2002;109(5):789–93.
33. Dahlen B, Roquet A, Inman M, et al. The contribution of histamine and leukotrienes to exercise induced airway obstruction in asthmatics [abstract]. Am J Respir Crit Care Med 2000;161(3 Suppl):A613.
34. Dahlen B, Kumlin M, Margolskee DJ, et al. The leukotriene-receptor antagonist MK-0679 blocks airway obstruction induced by inhaled lysine- aspirin in aspirin-sensitive asthmatics. Eur Respir J 1993;6(7):1018–26.
35. Dal CG, Martinati L, Mingoni S, et al. Salbutamol powder, administered via a multidose and a single- dose powder inhaler, in the prevention of exercise-induced asthma in children. Pediatr Asthma Allergy Immunol 1995;9(3):165–71.
36. Das S, Gunawardena K, Palmer P. Protection against exercise-induced asthma: a sensitive method to compare long acting ß2-agonist inhalers [abstract]. American Thoracic Society 99th International Conference; Seattle, WA, May 16–21, 2003;B036.
37. Daugbjerg P, Nielsen KG, Skov M, et al. Duration of action of formoterol and salbutamol dry-powder inhalation in prevention of exercise-induced asthma in children. Acta Paediatr 1996;85(6):684–7.
38. De Benedictis FM, Tuteri G, Pazzelli P, et al. Combination drug therapy for the prevention of exercise-induced bronchoconstriction in children. Ann Allergy Asthma Immunol 1998;80(4):352–6.
39. De Benedictis FM, del Giudice MM, Forenza N, et al. Lack of tolerance to the protective effect of montelukast in exercise-induced bronchoconstriction in children. Eur Respir J 2006;28(2):291–5.
40. De Benedictis FM, Tuteri G, Solinas LF, et al. Salmeterol in the prevention of exercise-induced asthma in children: comparing two doses [abstract]. Eur Respir J Suppl 1995;8 Suppl 19:519S.
41. Debelic M. Comparison of inhaled formoterol and fenoterol in prevention of exercise-induced asthma. Eur Respir J 1988;1(Suppl 2):381S.
42. Del Col G, Spezia E, Richelli C, et al. Assessment of a new space device (Jet) for use with inhaled beta2-agonists in children with exercise-induced asthma. Pediatr Asthma Allergy Immunol 1993;7(2):119–26.
43. Del BN, Quartieri F, Vibelli C. Aerosolized clenbuterol NAB 365 and salbutamol in exercise-induced asthma. Curr Med Res Opin 1979;6(4):237–43.
44. Del BN, Quartieri F, Brembilla E. Effect of tiaramide hydrochloride Thc on exercise-induced asthma eia. Curr Ther Res Clin Exp 1981;30 (Pt 4):578–86.
45. Del BN, Quartieri F, Vibelli C. Intravenous NAB 365 clenbuterol and terbutaline in exercise-induced bronchospasm EIB. Clin Allergy 1979;9(3):277–82.
46. Del CG, Mingoni S, Martinati LC, et al. Salbutamol adminstered via two different powder inhalers in the prevention of exercise induced asthma (EIA) in children [abstract]. Eur Respir J Suppl 1995;8(Suppl 19):519S.
47. Dessanges JF, Prefaut C, Taytard A, et al. The effect of zafirlukast on repetitive exercise-induced bronchoconstriction: the possible role of leukotrienes in exercise-induced refractoriness. J Allergy Clin Immunol 1999;104(6):1155–61.
48. Dinh Xuan A, Lebeau C, Roche R, Ferriere A, Chaussain M. Inhaled terbutaline administered via a spacer fully prevents exercise- induced asthma in young asthmatic subjects: a double-blind, randomized, placebo-controlled study. J Int Med Res 1989;17(6):506–13.
49. Djaballah K, Dessanges JF, Patalano F, et al. Protective effect of inhaled iralukast (a new LTD4 antagonist) on exercise-induced bronchospasm. Eur Respir J Suppl 1996;9 Suppl 23:272S.
50. Dockhorn RJ, Wagner DE, Burgess GL, et al. Proventil HFA provides protection from exercise-induced bronchoconstriction comparable to proventil and ventolin. Ann Allergy 1997;79(1):85–8.
51. dos Santos JM, Costa H, Stahl E, et al. Bricanyl Turbuhaler and Ventolin Rotahaler in exercise-induced asthma in children. Allergy 1991;46(3):203–5.
52. Duong M, Subbarao P, Otis J, et al. Relationship between exercise-induced bronchoconstriction and sputum eosinophillia during ciclesonide treatment in asthmatics [abstract]. American Thoracic Society 2005 International Conference; May 20–25; San Diego, CA 2005;B35.
53. Edelman JM, Turpin JA, DeLucca PT, et al. Comparison of oral montelukast, a leukotriene antagonist and inhaled salmeterol in exercise induced asthma (EIA) [abstract]. Eur Respir J 1998;12(Suppl 29):18S.
54. Eggleston PA, Bierman CW, Pierson WE, et al. A double blind trial of the effect of cromolyn sodium on exercise-induced bronchospasm. J Allergy Clin Immunol 1972;50(1):57–63.
55. Eggleston PA, McMahan SA. The effects of fenoterol, ephedrine and placebo on exercise-induced asthma. Chest 1978;73(6 Suppl):1006–8.
56. Eggleston PA, Bierman CW, Pierson WE, Stamm SJ, Van Arsdel PP. Pharmacologic modulation of exercise asthma: the role of Cromolyn Sodium. J Allergy 1971;47:96.
57. Emtner M, Johansson H, Holmback J. A randomised controlled trial of the effects of the quality of life physical capacity and exercise in adults with asthma after short term intervention [abstract]. Eur Respir J 2005;26(Suppl 49):Abstract 1172.
58. Ferrari M, Segattini C, Zanon R, et al. Comparison of the protective effect of formoterol and of salmeterol against exercise-induced bronchospasm when given immediately before a cycloergometric test. Respiration 2002;69(6):509–12.
59. Ferrari M, Balestreri F, Baratieri S, et al. Evidence of the rapid protective effect of formoterol dry-powder inhalation against exercise-induced bronchospasm in athletes with asthma. Respiration 2000;67(5):510–3.
60. Ferres J, Ma FR, Sanchez del RT, et al. Formoterol in the prevention of exercise induced asthma in children five hours before a running test [abstract]. Eur Respir J Suppl 1997;10(Suppl 25):222S.
61. Ferres J, Recoder O, Gispert J, et al. Two months treatment with beclomethasone 500 or 1000μg in exercise induced asthma in children [abstract]. Eur Respir J Suppl 1995;8(Suppl 19):468S.
62. Filipoviã M, Pljastiã-Kamenov S, Kekovoã P, et al. Action of salmeterol in exercise induced asthma in adolescents and young adults [abstract]. Eur Respir J 1998;12(Suppl 29):20S.
63. Filipovic MD, Cekic SS, Dimitrijevic OB. Protective effect of inhaled beclomethasone dipropionate (BDP) in asthmatic patients with exercise-induced bronchoconstriction (EIB) [abstract]. Eur Respir J Suppl 2002;20(Suppl 38):abstract 1924.
64. Finnerty JP, Wood BR, Thomson H, et al. Role of leukotrienes in exercise-induced asthma. Inhibitory effect of ICI 204219, a potent leukotriene D4 receptor antagonist. Am Rev Respir Dis 1992;145(4 Pt 1):746–9.
65. Fitch KD, Morton AR. Specificity of exercise in exercise-induced asthma. Br Med J 1971;4(787):577–81.
66. Forenza N, del Giudice MM, Decimo F, et al. Overtime effect of montelkast in asthmatic children with exercise-induced bronchoconstriction [abstract]. Eur Respir J 2005;26(Suppl 49):Abstract 1061.
67. Francis PW, Krastins IR, Levison H. Oral and inhaled salbutamol in the prevention of exercise-induced bronchospasm. Pediatrics 1980;66(1):103–8.
68. Freezer NJ, Croasdell H, Doull IJ, et al. Effect of regular inhaled beclomethasone on exercise and methacholine airway responses in school children with recurrent wheeze. Eur Respir J 1995;8(9):1488–93.
69. Fuglsang G, Hertz B, Holm EB. No protection by oral terbutaline against exercise-induced asthma in children: a dose-response study. Eur Respir J 1993;6(4):527–30.
70. Giustina A, Malerba M, Bresciani E, et al. Effect of two beta 2-agonist drugs, salbutamol and broxaterol, on the growth hormone response to exercise in adult patients with asthmatic bronchitis. J Endocrinol Invest 1995;18(11):847–52.
71. Goldberg JB, Böhning WS. Fenoterol hydrobromide delivered via HFA-MDI or CFC‐MDI in patients with asthma: a safety and efficacy comparison. Respir Med 2000;94(10):948–53.
72. Golice G, Klinger N, Ekholm B, et al. Prevention of exercise-induced asthma by salbutamol formulated in HFA-134a propellant. Aust N Z J Med 1998;28:259.
73. Green CP, Price JF. Prevention of exercise induced asthma by inhaled salmeterol xinafoate. Arch Dis Child 1992;67(8):1014–7.
74. Gronnerod TA, von Berg A, Schwabe G, et al. Formoterol via Turbuhaler gave better protection than terbutaline against repeated exercise challenge for up to 12 hours in children and adolescents. Respir Med 2000;94(7):661–7.
75. Grzelewski T, Jerzynska J, Stelmach I. Budesonide and montelukast once daily inhibits exercise induced bronchoconstriction in 6 to 18 year old children with asthma [abstract]. J Allergy Clin Immunol 2006;117(2 Suppl 1):S93.
76. Guerin JC, Germain M, Febvre N, et al. Protective effect of formoterol on exercise-induced bronchoconstriction 10 hours after inhalation [abstract]. Eur Respir J Suppl 1993;6(Suppl 17):201S.
77. Gunawardena K, Palmer P, Das S, et al. Comparison of long acting ß2 agonist inhalers for treatment of exercise induced bronchoconstriction (EIB) [abstract]. Eur Respir J 2003;22(Suppl 45):Abstract 1987.
78. Hartley JP, Charles TJ, Seaton A. Betamethasone valerate inhalation and exercise-induced asthma in adults. Br J Dis Chest 1977;71(4):253–8.
79. Haverkamp HC, Eldbridge MW, Miller JD, et al. Treatment of airway inflammation improves arterial blood gas status during exercise in habitually active asthmatics [abstract]. American Thoracic Society 2005 International Conference; May 20–25 2005; San Diego, California;B19.
80. Haverkamp HC, Dempsey JA, Pegelow DF, et al. Treatment of airway inflammation improves exercise pulmonary gas exchange and performance in asthmatic subjects. J Allergy Clin Immunol 2007;120(1):39–47.
81. Hawksworth RJ, Sykes AP, Faris M, et al. Albuterol HFA is as effective as albuterol CFC in preventing exercise-induced bronchoconstriction. Ann Allergy Asthma Immunol 2002;88(5):473–7.
82. Helenius I, Lumme A, Ounap J, et al. No effect of montelukast on asthma-like symptoms in elite ice hockey players. Allergy 2004;59(1):39–44.
83. Hendeles L, Erb TA, Bird S, et al. Post-exercise response to albuterol after addition of montelukast or salmeterol to inhaled fluticasone [abstract]. J Allergy Clin Immunol 2004;113(2 Suppl):S34.
84. Henriksen JM. Effect of inhalation of corticosteroids on exercise induced asthma: randomised double blind crossover study of budesonide in asthmatic children. Br Med J (Clin Res Ed) 1985;291(6490):248–9.
85. Henriksen JM, Dahl R. Effects of inhaled budesonide alone and in combination with low-dose terbutaline in children with exercise-induced asthma. Am Rev Respir Dis 1983;128(6):993–7.
86. Henriksen JM, Agertoft L, Pedersen S. Protective effect and duration of action of inhaled formoterol and salbutamol on exercise-induced asthma in children. J Allergy Clin Immunol 1992;89(6):1176–82.
87. Hermansen MN, Nielsen KG, Buchvald F, et al. Acute relief of exercise-induced bronchoconstriction by inhaled formoterol in children with persistent asthma. Chest 2006;129(5):1203–9.
88. Hills EA, Davies S, Geary M. Salmefamol and salbutamol in exercise-induced asthma in children. Br J Dis Chest 1976;70(2):78–82.
89. Ho Chu JY, Tuazon O, Martirez C, et al. Comparison of the protective efficacy of inhaled and oral procaterol on exercise-induced asthma [abstract]. Am J Respir Crit Care Med 2000;161(3 Suppl):A345.
90. Hodges ANH, Lynn BM, Koehle MS, et al. Effects of inhaled bronchodilators and corticosteroids on exercise induced arterial hypoxaemia in trained male athletes. Br J Sports Med 2005;39(12):917–20.
91. Hofstra WB, Neijens HJ, Duiverman EJ, et al. Dose-responses over time to inhaled fluticasone propionate treatment of exercise- and methacholine-induced bronchoconstriction in children with asthma. Pediatr Pulmonol 2000;29(6):415–23.
92. Hofstra WB, Sterk PJ, Neijens HJ, et al. Short term treatment with zafirlukast, sodium cromo-glycate or placebo in reducing exercise-induced bronchoconstriction in adolescent asthmatics [abstract]. Eur Respir J Suppl 1997;10(Suppl 25):220S.
93. Horn CR, Jones RM, Lee D, et al. Bronchodilator effect of disodium cromoglycate administered as a dry powder in exercise induced asthma. Br J Clin Pharmacol 1984;18(5):798–801.
94. Ioli F, Donner CF, Fracchia C, et al. A new bronchodilating agent, procaterol, in preventing exercise-induced asthma. Int J Clin Pharmacol Res 1986;6(5):389–96.
95. Jonasson G, Carlsen KH, Blomqvist P. Clinical efficacy of low-dose inhaled budesonide once or twice daily in children with mild asthma not previously treated with steroids. Eur Respir J 1998;12(5):1099–104.
96. Jonasson G, Carlsen KH, Hultquist C. Low-dose budesonide improves exercise-induced bronchospasm in schoolchildren. Pediatr Allergy Immunol 2000;11(2):120–5.
97. Jonasson G, Carlsen KH. Low dose inhaled budesonide in exercise induced asthma. Eur Respir J 1999;14(Suppl 30):194S.
98. Jones RS, Blackhall MI. Role of disodium cromoglycate (“Intal”) in treatment of childhood asthma. Arch Dis Child 1970;45(239):49–53.
99. Kalmanova E, Chuchalin A, Knyageskaya N, et al. Influence of long acting beta-2 agonist and sustained-release theophylline on exercise and resting metabolism in asthmatic patients [abstract]. Eur Respir J Suppl 1997;10(Suppl 25):350S.
100. Katsunuma T, Akashi K, Shibata A, et al. Effect of short-term treatment with low-dose of fluticasone on exercise-induced bronchoconstriction in children with asthma [abstract]. American Thoracic Society International Conference, San Diego, CA, May 19–24 2006;A157.
101. Kemp JP, Dockhorn RJ, Shapiro GG, et al. Montelukast once daily inhibits exercise-induced bronchoconstriction in 6- to 14-year-old children with asthma. J Pediatr 1998;133(3):424–8.
102. Kemp JP, Dockhorn RJ, Busse WW, et al. Prolonged effect of inhaled salmeterol against exercise-induced bronchospasm. Am J Respir Crit Care Med 1994;150(6 Pt 1):1612–5.
103. Kim JH, Lee SY, Kim HB, et al. Prolonged effect of montelukast in asthmatic children with exercise-induced bronchoconstriction. Pediatr Pulmonol 2005;39(2):162–6.
104. Kivity S, Onn A, Greif Y, et al. Nedocromil and exercise-induced asthma: acute and chronic effects. Isr Med Assoc J 1999;1(2):92–4.
105. Konig P, Eggleston PA, Serby CW. Comparison of oral and inhaled metaproterenol for prevention of exercise-induced asthma. Clin Allergy 1981;11(6):597–604.
106. Kumar AS. Salmeterol in exercise induced asthma. Indian Pediatr 1998;35(7):681–2.
107. La Grutta S, Cibella F, Morici G, et al. Benificial effects of aerobic training montelukast in children with mild to intermittent asthma [abstract]. Eur Respir J 2005;26(Suppl 49):Abstract 1050.
108. Laube BL, Edwards AM, Creticos PS, et al. Optimizing the acute protective effect of sodium cromoglycate aerosol in patients with allergen-induced and exercise-induced asthma. Eur Respir J Suppl 1996;9(Suppl 23):352S.
109. Lecheler J, Pfannebecker B, Ellers-Lenz B, et al. Prevention of exercise induced bronchoconstriction (EIB) by a fixed combination of disodium cromoglycate plus reproterol compared to montelukast [abstract]. Eur Respir J 2004;24(Suppl 48):443S.
110. Lecheler J, Pfannebecker B, Nguyen DT, et al. Prevention of exercise-induced asthma by a fixed combination of disodium cromoglycate plus reproterol compared with montelukast in young patients. Arzneimittelforschung 2008;58(6):303–9.
111. Leff JA, Bronsky EA, Kemp J, et al. Montelukast (MK-0476) improves patient global assessment and decreases beta-agonist requirements in patients with mild asthma and exercise-induced bronchoconstriction (EIB) [abstract]. Eur Respir J Suppl 1997;10(Suppl 25):438S.
112. Leff JA, Busse WW, Pearlman D, et al. Montelukast, a leukotriene-receptor antagonist, for the treatment of mild asthma and exercise-induced bronchoconstriction. N Engl J Med 1998;339(3):147–52.
113. Lockhart A, Djaballah K, Dessanges JF, et al. The protective effect of zafirlukast against exercise-induced asthma [abstract]. Eur Respir J Suppl 1997;10(Suppl 25):419S.
114. Lopes DSJM, Costa H, Stahl E, et al. Bricanyl R Turbuhaler R and Ventolinrho Rotahaler R in exercise-induced asthma in children. Allergy 1991;46(3):203–5.
115. Magnussen H, Rabe KF. The protective effect of low-dose inhaled fenoterol against methacholine and exercise-induced bronchoconstriction in asthma: a dose-response study. J Allergy Clin Immunol 1992;90(5):846–51.
116. Mahomedy YA, Cowling CGD, Boeree B. A comparison of the effects of orally administered M&B 22,948 Zaprinast and placebo on changes in ventilatory function in patients with exercise- induced bronchial asthma: a pilot study. Curr Ther Res Clin Exp 1986;40(4):750–60.
117. Makker HK, Lau LC, Thomson HW, et al. The protective effect of inhaled leukotriene D4 receptor antagonist ICI 204,219 against exercise-induced asthma. Am Rev Respir Dis 1993;147(6 Pt 1):1413–8.
118. Manning PJ, Watson RM, Margolskee DJ, et al. Inhibition of exercise-induced bronchoconstriction by MK-571, a potent leukotriene D4-receptor antagonist. N Engl J Med 1990;323(25):1736–9.
119. Manning PJ, Watson RM, Margolskee DJ, et al. The effect of a leukotriene D-receptor antagonist, MK‐571, on exercise-induced bronchoconstriction [abstract]. Eur Respir J Suppl 1990;3(Suppl 10):203S.
120. McFadden ER Jr., Lenner KA, Strohl KP. Postexertional airway rewarming and thermally induced asthma. New insights into pathophysiology and possible pathogenesis. J Clin Invest 1986;78(1):18–25.
121. McFadden ER Jr., Mills R. Prevention of exercise-induced bronchospasm with aerosolized albuterol. Curr Ther Res Clin Exp 1986;39(1):112–8.
122. Melo RE, Sole D, Naspitz C. Montelukast (MK) prevents immediate and late asthmatic responses to exercise [abstract]. J Allergy Asthma Immunol 2002;109(Suppl 1):242–3.
123. Meltzer EO, Baena-Cagnani CE, Chervinsky P, et al. Once-daily mometasone furoate administered by dry powder inhaler for the treatment of children with persistent asthma. Pediatr Asthma Allergy Immunol 2007;20(2):67–81.
124. Merck. Two investigational drugs in the prevention of airway constriction brought on by exercise in asthmatic patients. [Internet] 2005 June. [Cited 2009 Aug 31]. Available from: http://clinicaltrials.gov/ct2/show/NCT00127166
125. Millqvist E, Bengtsson U, Whagen O. Combining a beta2-agonist with a face mask to prevent exercise-induced bronchoconstriction. Allergy 2000;55(7):672–5.
126. Miraglia del GM, Forenza N, Capristo A, et al. Time effect of montelukast in the prevention of exercise-induced bronchoconstriction in children. Eur Respir J 2001;18(Suppl 33):119S.
127. Molimard M, Martinat Y, Rogeaux Y, et al. Improvement of asthma control with beclomethasone extrafine aerosol compared to fluticasone and budesonide. Respir Med 2005;99(6):770–8.
128. Morse JL, Jones NL, Anderson GD. The effect of terbutaline in exercise-induced asthma. Am Rev Respir Dis 1976;113(1):89–92.
129. Morton AR, Hahn AG, Fitch KD. Continuous and intermittent running in the provocation of asthma. Ann Allergy 1982;48(2):123–9.
130. Morton AR, Scott CA, Fitch KD. Rimiterol and the prevention of exercise-induced asthma. J Allergy Clin Immunol 1989;83(1):61–5.
131. Morton AR, Papalia SM, Morton PS, et al. The efficacy of the nebuhaler method of administration of terbutaline sulphate in the prevention and amelioration of exercise induced asthma. Aust J Sci Med Sport 1992;24(4):103–6.
132. Netzer N, Steinacker JM, Schuell K, et al. Protective effect of oral montelukast (M) in a fixed drug combination of inhaled sodium cromoglycate and reproterol (SCG+R) on exercise induced asthma (EIA). Am J Respir Crit Care Med 2000;161(3 Suppl):A613.
133. Newnham DM, Ingram CG, Earnshaw J, et al. Salmeterol provides prolonged protection against exercise-induced bronchoconstriction in a majority of subjects with mild, stable asthma. Respir Med 1993;87(6):439–44.
134. Nicolaescu V, Racoveanu C, Manicatide M. Effects of exercise on practolol-treated asthmatic patients. Eur J Clin Pharmacol 1973;6(1):3–8.
135. Novembre E, Frongia G, Lombardi E, et al. The preventive effect and duration of action of two doses of inhaled furosemide on exercise-induced asthma in children. J Allergy Clin Immunol 1995;96(6 Pt 1):906–9.
136. Orgel HA, Meltzer EO, Kemp JP. Flunisolide aerosol in treatment of steroid-dependent asthma in children. Ann Allergy 1983;51(1 Pt 1):21–5.
137. Ostrom NK, Larsen JS, Miller CJ, et al. Sustained attenuation of exercise-induced bronchoconstriction by Zafirlukast when administered with food. J Allergy Clin Immunol 2001;107(2):S112.
138. Patakas D, Louridas G, Sehletidis L. Effect of beclomethasone dipropionate inhalation on exercise induced bronchospasm. IRCS Med Sci Cardiovasc Syst 1978;6(11):448.
139. Patalano F, Tidmann U, Radermecker M. Foradil(r) (formoterol fumarate) 12 micrograms single dose prevents exercise induced bronchospasm over a period of 12 hours. Ann Allergy Asthma Immunol 1998;80:87.
140. Patalano F, Tidmann U, Radermecker M. Foradil® (formoterol fumarate) 12 micrograms single dose prevents exercise induced bronchospasm over a period of 12 hours. Ann Allergy Asthma Immunol 1998;80:87.
141. Patel K, Kerr R, MacDonald W, et al. The effect of thymoxamine and cromolyn sodium on postexercise bronchoconstriction in asthma. J Allergy Clin Immunol 1976;57(4):285–92.
142. Patessio A, Podda A, Carone M, et al. Protective effect and duration of action of formoterol aerosol on exercise-induced asthma. Eur Respir J 1991;4(3):296–300.
143. Pavord ID, Wisniewski A, Tattersfield AE. Inhaled frusemide and exercise induced asthma: evidence of a role for inhibitory prostanoids. Thorax 1992;47(10):797–800.
144. Pearlman D, Milgrom H, Andriano K, et al. Comparison of formoterol (Aerolizer®), albuterol (MDI) and placebo in the prevention of exercise-induced bronchospasm in pediatric patients [abstract]. Chest 2002;122(4 Suppl):114S.
145. Pearlman D, Qaqundah P, Matz J, et al. Fluticasone propionate/salmeterol and exercise-induced asthma in children with persistent asthma. Pediatr Pulmonol 2009;44(5):429–35.
146. Pearlman DS, Rees W, Schaefer K, et al. An evaluation of levalbuterol HFA in the prevention of exercise-induced bronchospasm. J Asthma 2007;44(9):729–33.
147. Pederson R, Agertoft L, Pederson S. Use of ehaled nitiric oxide (eNO) as a marker for anti‐inflammatory dose response of beclomethasone extrafine aerosol (Q) dosed once daily (50–100ug) in children with exercise induced asthma [abstract]. Eur Respir J 2003;22(Suppl 45):Abstract 1984.
148. Petersen R, Agertoft L, Pedersen S. Treatment of exercise-induced asthma with beclomethasone dipropionate in children with asthma. Eur Respir J 2004;24(6):932–7.
149. Petheram IS, Bierman CW, Cobley A, et al. Oral prophylaxis of exercise induced asthma: a study of two new drugs. Br J Dis Chest 1980;74:319–20.
150. Petrovic V, Rebic P, Savic J, et al. Protective effect of fenoterol, cromolyn and their combination on exercise-induced asthma [abstract]. Eur Respir J Suppl 1995;8(Suppl 19):260S.
151. Pfleger A, Eber E, Weinhandl E, et al. Comparison of the preventive effects of nedocromil and salbutamol on the broncial response to cold dry air challenge in children with exercise-induced asthma [abstract]. Am J Respir Crit Care Med 2000;161(3 Suppl):A38.
152. Pin L, Bozel P, Ceugniet F, et al. Effect of 2 physical training programmes on oxygen consumption and exercise-induced asthma in asthmatic teenagers [abstract]. Eur Respir J Suppl 1993;6(Suppl 17):613S.
153. Pohl WR, Vetter N, Zwick H, et al. Adjustable maintenance dosing with budesonide/formoterol or budesonide: double-blind study. Respir Med 2006;100(3):551–60.
154. Poppius H, Salorinne Y. Comparative trial of salbutamol and an anticholinergic drug, SCH 1000, in prevention of exercise-induced asthma. Scand J Respir Dis 1973;54(3):142–7.
155. Rabe KF, Jorres R, Magnussen H. The effect of 10, 50 and 200 micrograms inhaled fenoterol on exercise induced asthma. Clin Exp Allergy 1993;23(5):440–5.
156. Raissy HH, Harkins M, Kelly F, et al. Pretreatment with albuterol versus montelukast for exercise-induced bronchospasm in children. Pharmacotherapy 2008;28(3):287–94.
157. Ramage L, Ingram C, Cree IA, et al. Chronic dosing with inhaled salmeterol in exercise induced asthma. Scott Med J 1992;37(5):155.
158. Reinhardt D, Ludwig J, Braun D, et al. Effects of the antiallergic drug ketotifen on bronchial resistance and beta-adrenoceptor density of lymphocytes in children with exercise-induced asthma. Dev Pharmacol Ther 1988;11(3):180–8.
159. Reiss TF, Hill JB, Harman E, et al. Increased urinary excretion of LTE4 after exercise and attenuation of exercise-induced bronchospasm by montelukast, a cysteinyl leukotriene receptor antagonist. Thorax 1997;52(12):1030–5.
160. Riccioni G, Ballone E, D’Orazio N, et al. Effectiveness of montelukast versus budesonide on quality of life and bronchial reactivity in subjects with mild-persistent asthma. Int J Immunopathol Pharmacol 2002;15(2):149–55.
161. Richter K, Janicki S, Jorres RA, et al. Acute protection against exercise-induced bronchoconstriction by formoterol, salmeterol and terbutaline. Eur Respir J 2002;19(5):865–71.
162. Richter K, Janicki S, Jörres RA, Magnussen H. The acute effects of formoterol, salmeterol and terbutaline on airway tone and protection against exercise-induced asthma [abstract]. Am J Respir Crit Care Med 2000;161(3 Suppl):A613.
163. Robertson W, Simkins J, O’Hickey SP, et al. Does single dose salmeterol affect exercise capacity in asthmatic men? Eur Respir J 1994;7(11):1978–84.
164. Robuschi M, Scuri M, Spagnotto S, et al. The protective effect of transdermal broxaterol on exercise-induced bronchoconstriction. Eur J Clin Pharmacol 1995;47(5):465–6.
165. Sanguinetti CM, De Luca S, Gasparini S, Massei V. Evaluation of Duovent in the prevention of exercise-induced asthma. Respiration 1986;50(Suppl 2):181–5.
166. Schaanning J, Vilsvik J, Henriksen AH, et al. Efficacy and duration of salmeterol powder inhalation in protecting against exercise-induced bronchoconstriction. Ann Allergy Asthma Immunol 1996;76(1):57–60.
167. Schaanning J, Vilsvik J, Henriksen AH. The efficacy of salmeterol in protecting against exercise induced bronchoconstriction: a double blind placebo control cross-over study comparing the effect of placebo and salmeterol at 4, 8 and 12 hours after medication [abstract]. Eur Respir J Suppl 1994;7(Suppl 18):113S.
168. Schmidt A, Diamant B, Bundgaard A, et al. Ergogenic effect of inhaled beta 2-agonists in asthmatics. Int J Sports Med 1988;9(5):338–40.
169. Sepracor Inc. Efficacy study of single-dose levalbuterol tartrate hydrofluoroalkane (HFA) metered dose inhaler (MDI) versus placebo in prevention of exercise-induced bronchospasm (EIB) in subjects 18 years of age and older with exercise- induced bronchospasm. [Internet] 2005 Dec. [Cited 2009 Sep 3]. Available from: http://www.clinicaltrials.gov/ct2/show/NCT00268723
170. Shapiro GG, McPhillips JJ, Smith K, et al. Effectiveness of terbutaline and theophylline alone and in combination in exercise-induced bronchospasm. Pediatrics 1981;67(4):508–13.
171. Shapiro GG, Kemp JP, DeJong R, et al. Effects of albuterol and procaterol on exercise-induced asthma. Ann Allergy 1990;65(4):273–6.
172. Shapiro GS, Yegen U, Xiang J, et al. A randomized, double-blind, single-dose, crossover clinical trial of the onset and duration of protection from exercise-induced bronchoconstriction by formoterol and albuterol. Clin Ther 2002;24(12):2077–87.
173. Sheppard D, Nadel JA, Boushey HA. Inhibition of sulfur dioxide-induced bronchoconstriction by disodium cromoglycate in asthmatic subjects. Am Rev Respir Dis 1981;124(3):257–9.
174. Shostakovich-Koretskaya L, Cherginets A. Effect of long-term treatment with inhaled furosemide and nedocromil sodium on exercise-induced broncho‐obstruction in asthmatic children. Eur Respir J 2001;18(Suppl 33):495S.
175. Sichletidis L, Daskalopoulou E, Kyriazis G, et al. Comparative efficacy of salbutamol and salmeterol in exercise-induced asthma. J Int Med Res 1993;21(2):81–8.
176. Sly RM, O’Brien SR. Effect of oral terbutaline on exercise-induced asthma. Ann Allergy 1982;48(3):151–5.
177. Sly RM, Schlumbrecht L. Exercise-induced bronchospasm: comparison of bronkephrine and epinephrine. Ann Allergy 1968;26(9):493–8.
178. Sly RM, Puapan P, Ghazanshahi S, et al. Exercise-induced bronchospasm: evaluation of albuterol aerosol. Ann Allergy 1975;34(1):7–14.
179. Smolenov IV, Stakhanova SA, Ogorodova LM, et al. Prevention of exercise-induced bronchospasm in children with asthma: a comparison of different anti-inflammatory combination therapy [abstract]. Eur Respir J Suppl 2002;20(Suppl 38):abstract 2402.
180. Snijders D, Panizzolo C, Galesso P, et al. Urinary leukotriene E4 after training exercise in children with asthma [abstract]. Eur Respir J 2006;28(Suppl 50):478S.
181. Soferman R, Kivity S, Marcus B, et al. Comparison between bronchial response to inhaled hypoosmolar and isoosmolar solutions of sodium cromoglycate after exercise challenge. Ann Allergy 1990;64(2 Pt 1):143–6.
182. Steinshamn S, Sandsund M, Sue-Chu M, et al. Effects of montelukast on physical performance and exercise economy in adult asthmatics with exercise- induced bronchoconstriction. Scand J Med Sci Sports 2002;12(4):211–7.
183. Steinshamn SL, Sandsund M, Sue-Chu M, et al. Effects of montelukast on cardiopulmonary ergonomy and physical performance during exercise in adult asthmatics with exercise-induced bronchoconstriction: a comparative study with salmeterol [abstract]. Chest 2002;122(4):185S.
184. Stelmach I, Grzelewski T, Majak P, et al. Effect of different antiasthmatic treatments on exercise-induced bronchoconstriction in children with asthma. J Allergy Clin Immunol 2008 Feb;121(2):383–9.
185. Stensrud T, Nordahl B, Vilberg A, et al. Maximal oxygen uptake testing, a comparison of two test protocols [abstract]. American Thoracic Society 2005 International Conference; May 20–25; San Diego, California 2005;B65.
186. Sturani C, Schiavina M, Tosi I, et al. Comparison of inhaled fenoterol and salbutamol in the prevention of exercise-induced asthma. Eur J Respir Dis Suppl 1983;128(Pt 2):526–8.
187. Subbarao P, Duong M, Otis J, et al. Ciclesonide attenuates exercise-induced bronchconstriction over time in asthmatic subjects [abstract]. American Thoracic Society 2005 International Conference; May 20–25; San Diego, California 2005;B35.
188. Subbarao P, Duong M, Adelroth E, et al. Effect of ciclesonide dose and duration of therapy on exercise-induced bronchoconstriction in patients with asthma. J Allergy Clin Immunol 2006;117(5):1008–13.
189. Subbarao P, Duong M, Pedersen S, et al. Once daily ciclesonide protects against exercise-induced bronchoconstriction [abstract]. XIX World Allergy Organization Congress, June 26-July 1, Munich, Germany 2005.
190. Subbarao PJ, Duong M, Otis J, et al. Ciclesonide is effective in protecting against exercise-induced bronchoconstriction [abstract]. J Allergy Clin Immunol 2005;115(2 Suppl):S1.
191. Sue-Chu M, Karjalainen EM, Laitinen A, et al. Placebo-controlled study of inhaled budesonide on indices of airway inflammation in bronchoalveolar lavage fluid and bronchial biopsies in cross-country skiers. Respiration 2000;67(4):417–25.
192. Svenonius E, Arborelius M, Wiberg R, et al. A comparison of terbutaline inhaled by Turbuhaler and by a chlorofluorocarbon CFC inhaler in children with exercise-induced asthma. Allergy 1994;49(6):408–12.
193. Tammivaara R. The efficacy of terbutaline and fenoterol aerosols on adult exercise-induced asthma. Scand J Respir Dis Suppl 1979;103:212–3.
194. Tan WC, Lim TK. Double-blind comparison of the protective effect of sodium cromoglycate and ketotifen on exercise-induced asthma in adults. Allergy 1987;42(4):315–7.
195. Thomson NC, Green AG, Kerr JW. Effect of FPL57787 in exercise-induced asthma. Clin Allergy 1980;10(1):43–6.
196. Tsoy AN, Cheltzov VV, Zaseyeva OV, et al. Preventive effect of formoterol aerosol in exercise-induced broncho-constriction [abstract]. Eur Respir J Suppl 1990;3(Suppl 10):235S.
197. Tullett WM, Patel KR. Isosorbide dinitrate and isoxsuprine in exercise induced asthma. Br Med J (Clin Res Ed) 1983;286(6382):1934–5.
198. Turcotte H, Archambault F, Rigali F, et al. Influence of a low dose of BDP-HFA on methacholine or exercise-induced lung hyperinflation in mild asthma [abstract]. Eur Respir J 2005;26(Suppl 49):Abstract 3317.
199. Turpin JA, Edelman JM, DeLucca PT, et al. Chronic administration of montelukast (MK-476) is superior to inhaled salmeterol in the prevention of exercise-induced bronchoconstriction (EIB). Am J Respir Crit Care Med 1998;157(3 Suppl):A456.
200. Vige R, Carlsen K-H, Ingjer F. The effect of the leukotriene receptor antagonist Montelukast on endurance performance in healthy non-asthmatic endurance trained athletes. Eur Respir J 2001;18(Suppl 33):491S.
201. Vilsvik J, Schaanning J, Stahl E, et al. Comparison between Bricanyl Turbuhaler and Ventolin metered dose inhaler in the treatment of exercise-induced asthma in adults. Ann Allergy 1991;67(3):315–8.
202. Vilsvik J, Ankerst J, Palmqvist M, et al. Protection against cold air and exercise-induced bronchoconstriction while on regular treatment with Oxis. Respir Med 2001;95(6):484–90.
203. Vilsvik J, Ankerst J, Palmqvist M, et al. Protection against exercise-induced bronchoconstriction during regular treatment with formoterol turbuhaler® B.I.D in adult asthmatics. Eur Respir J Suppl 1999;14(Suppl 30):1085S.
204. Vilsvilk J, Schaanning J, Stahl E, et al. Exercise-induced asthma in adult patients: a comparison between Bricanyl, Turbuhaler and Ventolin metered dose inhaler (MDI) [abstract]. Eur Respir J Suppl 1990;3(Suppl 10):71S.
205. Walker SB, Bierman CW, Pierson WE, et al. Bitolterol mesylate in exercise-induced asthma. J Allergy Clin Immunol 1986;77(1 Pt 1):32–6.
206. Ward FG, Gomes S, McNeill RS. Disodium cromoglycate in exercise-induced asthma. Br Med J 1969;3(663):176–7.
207. Weiler JM, Nathan RA, Rupp NT, et al. Effect of fluticasone/salmeterol administered via a single device on exercise-induced bronchospasm in patients with persistent asthma. Ann Allergy Asthma Immunol 2005;94(1):65–72.
208. Weinberg EG. The effect of terbutaline sulphate on exercise-induced asthma in children. S Afr Med J 1982;61(16):587–9.
209. Weinbren I, Bound J, Capper L. A double-blind trial of disodium cromoglycate in bronchial asthma wh assessment by four observers. Br J Dis Chest 1969;63(3):155–64.
210. Wilson N, Dixon C, Silverman M. Bronchial responsiveness to hyperventilation in children with asthma: inhibition by ipratropium bromide. Thorax 1984;39(8):588–93.
211. Yazigi R, Sly RM, Frazer M. Effect of triamcinolone acetonide aerosol upon exercise-induced asthma. Ann Allergy 1978;40(5):322–5.
212. Yegen U, Shapiro G, Xiang X, et al. Foradil aeroliser provides rapid and long acting protection against exercise-induced bronchospasm. Am J Respir Crit Care Med 1998;157(3 Suppl):A92.
213. Zimmermann T, Viel K. An open randomized cross-over study to assess protection of salmeterol vs dinatriumcromoglycat in children with exercise induced asthma. Annual Thoracic Society 97th International Conference; San Francisco CA, May 18–23 2001.
214. Zimmermann T, Gulyas A, Bauer CP, et al. Salmeterol versus sodium cromoglycate for the protection of exercise induced asthma in children-a randomised cross-over study. Eur J Med Res 2003;8(9):428–34.

## Comparison (n = 2)

1. Almahroos G, Watts TP, Joshi RC. Ketotifen and di‐sodium cromoglycate in the prevention of exercise induced asthma [abstract]. Clin Sci 1986;71(Suppl 15):9P.
2. Lilja G, Graff-Lonnevig V, Bevegard S. Comparison of the protective effect of ketotifen and disodium cromoglycate on exercise-induced asthma in asthmatic boys. Allergy 1983;38(1):31–5.

## Outcome (n = 1)

1. Grove A, McFarlane LC, Lipworth BJ. Expression of the beta 2 adrenoceptor partial agonist/antagonist activity of salbutamol in states of low and high adrenergic tone. Thorax 1995;50(2):134–8.

## Language (n = 38)

1. [Tolerance for salmeterol in exercise-induced asthma]. Geneesmiddelenbulletin 1999;33(2):20–1.
2. Aebischer JC, Benoit RC, Scherrer M. [Pirbuterol and salbutamol aerosol for exercise-induced bronchoconstriction]. Schweiz Med Wochenschr 1984;114(46):1660–4. German.
3. Agostini M, Barlocco G, Mastella G. [Protection against exercise induced asthma in children. Double blind controlled clinical trial with fenoterol spray, fenoterol plus ipratropium and oral clenbuterol]. Riv Ital Pediatr 1983;9(4):347–52. Italian.
4. Battistini A, Grzincich GL, Gorni A, Baroni AL. Asthma and bronchodilator drugs. Evaluation of a newly developed betasub 2-agonist: Clenbuterol. [Asma da sforzo e broncodilatatori. Valutazione strumentale di un nuovo Beta2 stimolante: il clenbuterolo]. Riv Ital Pediatr 1980;6(3):313–9. Italian.
5. Bauer C, P. [Therapy of exercise-induced asthma with Cromoglicinic acid disodium salt DNCG]. Padiatrische Praxis 1984;30:597–601. German.
6. Bauer CP, Emmrich P. [Effect of nedocromil sodium on the hyperreactivity of the bronchial system in young asthmatic patients]. Monatsschr Kinderheilkd 1988;136(12):810–4. German.
7. Baur X. [Bronchial asthma induced by exercise]. Dtsch Med Wochenschr 1981;106(10):301–4. German.
8. Boner AL, Zamo CR, Marchiori MM, et a l. [Comparison of nebulized ipratropium, salbutamol and cromoglicate solutions, cromoglicate inhaled powder, theophylline elixir and placebo in exercise induced asthma of the children]. G Ital Mal Torace 1984;38(6):395–9. Italian.
9. Boye NP. Disodium cromoglycate and exercise induced airway obstruction. Tidsskr Nor Laegeforen 1973;93(12):840–2.
10. Corrias A, Pelosi U, Corona GB, et al. [Efficacy of broxaterol vs salbutamol in asthma induced by physical exercise in children]. Pediatr Med Chir 1989;11:161–3. Norwegian.
11. Cropp GJ, A. [Relative effectivity of inhalation of Isoprenalin and Disodium Chromoglycicum on exercise-induced asthma]. Monatsschr Kinderheilkd 1976;124:234–7. German.
12. Dal CG, Martinati L, Mingoni S, et al. [Salbutamol powder, administered via a multidose and a single- dose powder inhaler, in the prevention of exercise-induced asthma in children]. Rev Bras Med 2002;59(6):462–6. Portuguese.
13. Debelic M, Stechert R. [Exercise-induced asthma— protection with disodium cromoglycate alone and in combination with fenoterol]. Monatsschr Kinderheilkd 1988;136(8):448–52. German.
14. Delnitz D, Rozniecki J, Grabski W. [Comparative evaluation of the effects of sodium cromoglycate and ketotifen on exercise-induced bronchospasm in patients with asthma]. Pneumonol Pol 1985;53(4):192–4. Polish
15. Delnitz D, Rozniecki J. [Pharmacological prevention of exercise-induced bronchospasm in patients with asthma]. Pneumonol Pol 1985;53(4):185–91. Polish.
16. Fu YX, Ye ST, Xia LY. [The effect of sodium cromoglycate in the prevention of exercise-induced asthma]. Zhonghua Jie He He Hu Xi Za Zhi 1985;24(10):577–9. Chinese.
17. Gehrke I, Bohm E, Sybrecht GW. [Stress-induced asthma—placebo-controlled double-blind comparison of prevention using fenoterol, disodium cromoglycate and a combination of the two]. Prax Klin Pneumol 1986;40(4):129–34. German.
18. Gmur H, Scherrer M. [Protection from exertion-induced bronchial asthma with disodium cromoglycate DSCG cromolyn, lomudal, intal and with ketotifen zaditen. Doubly crossed double-blind study]. Schweiz Med Wochenschr 1979;109:881–4. German.
19. Guerin JC, Flandrois R. [A study of berodual protector effect on asthma induced by exercise, by placebo and disolic cromoglycate comparison]. Rev Mal Respir 1989;6(Suppl 1):R37. French.
20. Guerin JC, Brambilla C, Godard P, et al. [Prolonged effect against exercise-induced bronchospasm: salmeterol versus sodium cromoglycate]. Rev Mal Respir 1992;9(Suppl 1):R27–R30. French.
21. Hertz B, Fuglsang G, Holm EB. [Exercise-induced asthma in children and oral terbutaline. A dose-response relationship study]. Ugeskr Laeger 1994;156(39):5693–5. Danish.
22. Jenssen AO. [Broncholytic effects of salbutamol and isoprenaline aerosol given to asthmatics before exercise]. Tidsskr Nor Laegeforen 1972;92(16):1104–7. Norwegian.
23. Joppich R. [Comparison of the effects of reproterol, oxitropium bromide, disodium cromoglycate and theophylline in the prevention of exercise-induced asthma in children]. Atemwegs- und Lungenkrankheiten 1987;13(9):453–6. German.
24. Koenig P, Abramov A, Godfrey S. [Exercise‐ induced asthma as an objective criterion for assessing response to disodium cromoglycate]. Harefuah 1971;81(3):127–30. Hebrew.
25. Lecheler J, Biberger A, Seligmann C, et al. [Sports therapy in the treatment of pediatric bronchial asthma. Comparison of interval and continuous training]. Prax Klin Pneumol 1988;42(7):475–8. German.
26. Magnussen H, Reuss G. [Blockade of exercise- induced bronchial asthma by fenoterol]. Klin Wochenschr 1984;62(4):168–74. German.
27. Negele K, Stein D, Grubl A, Bauer CP. [Value of Montelukast in comparison to Nedocromil-NA in exercise-induced Asthma]. Klin Padiatr 2000;212(5):S80. German.
28. Petrov VI, Smolenov IV, Alikova OA, et al. [Step‐by-step management of bronchial asthma children: step up or step down?] Pulmonology 2000;2(C). Russian.
29. Rampulla C, Bruschi C, Zoia MC. [Calcium‐antagonists and exercise-induced bronchoconstriction (EIB): immediate and late effects of nifedipine, in comparison with salbuamol and DSCG]. Folia Allergologica et Immunologica Clinica 1985;32(4):271–7. Italy.
30. Scherrer M, Zeller C, Kyd K, Geiser M. [Budesonide Pulmicort and exertion-induced asthma]. Schweiz Med Wochenschr 1986;116(23):775–81. German.
31. Sienra Monge JJ, Bermejo Guevara MA, Espinola RG, et al. [Effect of heating on FEV-1 in children with asthma challenged with exercise]. Rev Alerg Mex 2000;47(2):75–9. Spanish.
32. Sin HL, Jae JS, Sang YL, et al. [The protective effect of inhaled heparin, cromolyn, budesonide, and furosemide on exercise-induced asthma]. Zhonghua Jie He He Hu Xi Za Zhi 1998;45(6):1188–98. Korean.
33. Spada EL, Donner CF, Meriggi A, Vecchio C. [Pharmacologic prevention of exercise-induced asthma]. Minerva Pneumol 1985;24(2):159–64. Italy.
34. Stemmann EA, Weihermann D, Schachoff R. [Prophylactic treatment of exercise-induced asthma]. Med Welt 1981;32(24):981–4. German.
35. Todaro A, Rossi A. [Formoterol for the treatment of the asthmatic athletes]. Med Sport (Roma) 2002;55(3):189–94. Italian.
36. Vazquez C, Fidalgo I, Virto MC, et al. [Effectiveness of disodium cromoglycate, salbutamol, and ipratropium bromide in the inhibition of exercise-induced bronchospasm]. An Esp Pediatr 1984;20(8):756–62. Spanish.
37. Viallat JR, Razzouk H, Boutin C. [A double-blind study of sodium chromoglycate preventive effect of sodium chromoglycate on children with post‐exercise asthma]. Rev Mal Respir 1985;2(2):111. French.
38. von Berg A, Albrecht B, Darlath W, et al. [Intraindividual randomised double-blind comparison between sodium cromoglycate and reproterol to assess the protective effect of the single drugs and their combination in children with exercise induced asthma]. Allergologie 2002;25(11):557–64. German.

## Insufficient Data (n = 12)

1. Cekic SS, Filipovic MD, Dimitrijevic OB. Comparison of salbutamol, nedocromil sodium and disodium cromoglycate (DSCG) protective effects in patients with exercise induced bronchoconstriction (EIB). Eur Respir J 2002;20(Suppl 38):306S.
2. Coreno AJ, Skowronski ME, Kotaru C, et al. Comparative effects of single doses of anti‐ leukotrienes and long acting references.r2- agonists on exercise induced asthma (EIA) [abstract]. Am J Respir Crit Care Med 2000;161(3 Suppl):A613.
3. Filipovic M, Kamenov S, Kamenov B, et al. Comparative efficacy of cromolyn and salbutamol in exercise induced asthma. Eur Respir J Suppl 1999;14(Suppl 30):1385.
4. Hartley JPR, Davies BH, Nogrady SG. The effect of anticholinergic and H1 receptor blockade on exercise-induced asthma. Br J Dis Chest 1980;74:315–6.
5. Johnson CE, Belfield PW, Davis S, et al. Platelet activation during exercise induced asthma: effect of prophylaxis with cromoglycate and salbutamol. Thorax 1986;41(4):290–4.
6. Kendall MJ. The Problem of salmeterol. University Hospital Birmingham NHS Trust 2001 Mar 14;14/03/2002 End date(Unknown):Complete.
7. Lee T, Mant T, Amin D, et al. A single dose (4 mg) of CFC-free nedocromil sodium is effective against exercise-induced bronchoconstriction (EIB) in asthmatic volunteers [abstract]. Eur Respir J Suppl 1997;10(Suppl 25):128S.
8. Ostrom N, Bronsky E, Pearlman D, et al. Effects of the leukotriene-receptor antagonist zafirlukast on exercise-induced asthma in pediatric subjects [abstract]. Eur Respir J Suppl 1997;10(Suppl 25):276S.
9. Pearlman D, Greos L, Olson G, et al. A single-dose efficacy comparison of albuterol-HFA-BOI and albuterol-HFA-MDI in adolescents and adults with exercise-induced bronchospasm (EIB) [abstract]. American Thoracic Society 2005 International Conference; May 20–25; San Diego, California 2005;B36.
10. Pearlman DS, Ostrom NK, Bronsky EA, et al. Efficacy and safety of zafirlukast (Accolate®) in pediatric patients with exercise-induced asthma. Ann Allergy Asthma Immunol 1997;78:113.
11. Shapiro GG, DuHamel TR, Wighton TG, et al. The childhood asthma management program (CAMP): design, rationale, and methods. Control Clin Trials 1999;20(1):91–120.
12. Weiner P, Greif J, Fireman E, et al. Bronchodilating effect of cromolyn sodium in asthmatic patients at rest and following exercise. Ann Allergy 1984;53(2):186–8.

## Duplicate Publication (n = 9)

1. De Benedictis FM, Tuteri G, Niccoli A, et al. The protective effect and the duration of action of cromolyn and nedocromil sodium on exercise-induced asthma in children [abstract]. Eur Respir J Suppl 1994;7(Suppl 18):140S.
2. Godfrey S, Konig P. Suppression of exercise-induced asthma by salbutamol, theophylline, atropine, cromolyn, and placebo in a group of asthmatic children. Pediatrics 1975;56(5 suppl):930–4.
3. Hancox RJ, Subbarao P, Kamada D, et al. Beta-agonist tolerance and exercise-induced bronchospasm. Am J Respir Crit Care Med 2002;165(Suppl 8):A185.
4. Hancox RJ, Subbarao P, Kamada D, et al. Beta2‐agonist tolerance and exercise-induced bronchospasm. Am J Respir Crit Care Med 2002;165(8 Suppl):A185.
5. Johnson O, van Adelsberg J, Pearlman DS, et al. Onset and duration of single-dose protection of montelukast against exercise-induced bronchospasm [abstract]. J Allergy Clin Immunol 2005;115(2 Suppl):S11.
6. Patel KR, Tullett WM, Neale MG, et al. Plasma concentrations of sodium cromoglycate given by nebulisation and metered dose inhalers in patients with exercise-induced asthma: relationship to protective effect. Br J Clin Pharmacol 1986;21(2):231–3.
7. Pearlman DS, Philip G, Johnson O, et al. Protection against exercise-induced bronchospasm by a single dose of montelukast [abstract]. American Thoracic Society 2005 International Conference; May 20–25; San Diego, California 2005;B36.
8. Peroni DG, Piacentini GL, Ress M, et al. Time efficacy of a single dose of montelukast on exercise-induced asthma in children. Pediatr Allergy Immunol 2002;13(6):434–7.
9. Rachelefsky GS, Tashkin DP, Katz RM, et al. A Comparison of aerosolized atropine, isoproterenol, atropine plus isoproterenol, disodium cromoglycate and placebo in the prevention of exercise-induced asthma. Chest 1978;73(6 Suppl):1017–9.

## Unable to Retrieve (n = 13)

1. Bach-Mortensen N, Bundgaard A, Schmidt A. Ipratropium (Atrovent) treatment (alone and in combination) in children with exercise-induced asthma. Postgrad Med J 1987;63(Suppl 1):11A.
2. Cooper DM, Atlas AB. Effectiveness of single dose pre-exercise treatment with montelukast in children with exercise induced asthma [abstract]. American Thoracic Society 100th International Conference, May 21–26, 2004, Orlando 2004;A53.
3. Dinh Xuan AT, Campagnon A, Summerton L, et al. Attenuation of exercise-induced asthma but not exercise induced increases in exhaled oxide output by zafirlukast (Accolate™) [abstract]. Am J Respir Crit Care Med 1998;157(3 Suppl):A624.
4. Flynn D. Proposal for a series of n of 1 trials of the bronchodilator effect of the Leucotriene receptor antagonist (LTRA) montelukast (ML) in childhood asthma. Barking, Havering and Redbridge Hospitals NHS Trust 2003.
5. GlaxoSmithKline. A study to determine the duration of action of inhaled salmeterol during exercise challenge tests in asthmatic children. [Internet] 2005 July. [Cited 2009 Sept 3]. Available from: http://www.clinicaltrials.gov/ct2/show/NCT00118690.
6. Gronnerod TA, Hamre HS, Oepen G, et al. Protective effect of single doses of formoterol turbuhaler® 4.5 microgramm and 9 microgramm in children with exercise-induced bronchoconstriction. Eur Respir J Suppl 1999;14(Suppl 30):352.
7. Kim JH, Kim BS, Choi SO, et al. Clinical and bronchoprotective effects of montelukast in children with exercise-induced asthma [abstract]. American Thoracic Society 99th International Conference 2003;B036.
8. Morgan M. A comparison of the efficiency of Salmeterol xinofoate with oral salbutamol controlled release against exercise induced asthma in adult asthmatics. University Hospitals of Leicester NHS Trust 1994.
9. Pearlman DS, Rees W, Huang H, et al. An evaluation of levalbuterol HFA in the prevention of exercise-induced brochospasm [abstract]. Chest 2006;130(4):163S.
10. Richter K, Jorres RA, Janicki S, et al. Protection against exercise-induced asthma by the inhaled luekotriene D4-receptor antagonist bay X7195 [abstract]. Am J Respir Crit Care Med 1998;157(3 Suppl):A409.
11. Silverman M. Management of asthma in schoolchildren: role of montelukast and salmeterol at step 3 of the BTS guidelines: a double blind randomised controlled trial using exercise induced asthma as outcome. To compare the efficacy of two medications currently used for persistent exercise induced asthma in school children 2000.
12. Thio BJ, Slingerland GLM, Nagelkerke AF, et al. Single high dose inhaled fluticasone propionate (FP) reduces exercise induced bronchial obstruction (EIB). Am J Respir Crit Care Med 1998;157(3 Suppl):A710.
13. West J. A secondary care based study to examine the effect of salmeterol vs. salbutamol in exercise induced asthma in children 1998.