# Literature Search Strings

Table B1 Diagnosis of EIB/EIA review – OVID Databases

Search Date: November 20, 2008
Number of Results: 3640
Database | Years Searched | Number of Results
AMED (Allied and Complementary Medicine) | 1985 to November 2008 | 21
PsycINFO | 1806 to November Week 3 2008 | 14
MEDLINE^®^ | 1950 to November Week 2 2008 | 2321
EMBASE | 1988 to 2008 Week 46) | 1006
PASCAL | 1987 to October 2008 | 179
EBM Reviews - Cochrane Central Register of Controlled Trials | 4^th^ Quarter 2008 | 99
MULTIFILE STRATEGY; 1. exp “Exercise Induced Asthma”/or exp Asthma, Exercise-Induced/; 2. (“induced bronchoconstriction” or “induced asthma” or “induced bronchospasm”).kw,ie,id,sh. and (exercise* or (train* and (military or army)) or fitness or “physical activity” or exertion or athlet* or sport*).mp.; 3. (bronchoconstrict* or asthma* or antiasthma* or wheez* or (respiratory adj sound?) or (bronchial adj5 (spasm* or constrict*)) or bronchospas* or “bronchial hyperreactivity” or “respiratory hypersensitivity”).mp.; 4. ((bronchial* or respiratory or airway* or lung*) adj5 (hypersensitiv* or hyperreactiv* or allerg* or insufficiency)).mp.; 5. or/3–4; 6. (EIB or EIA).ti,ab.; 7. ((exercise adj5 induced) or “exercised-induced” or (exercise adj5 challenge) or “exercise tolerance” or “physical exercise” or (train* and (military or army)) or fitness or “physical activity” or exertion or athlet* or sport*).mp,jn. or exp Sports/or Exercise/; 8. or/6–7; 9. and/5,8; 10. or/1–2,9; 11. (sensitiv* or diagnos* or predictive value* or probability).mp.; 12. (accurac* or specificity).tw.; 13. ((pre-test or post-test) adj probability).mp.; 14. likelihood ratio*.mp.; 15. di.fs.; 16. *Diagnostic Accuracy/; 17. (mannitol or methacholine or MCT or EVH or eucapnic or hyperpnea* or FRAST or provocation or marker* or screen* or test*).mp.; 18. or/11–17; 19. 18 and 10; 20. limit 19 to english language; 21. limit 20 to human; 22. remove duplicates from 21

Table B2 Diagnosis of EIB/EIA review – EBSCO Databases

Search Date: November 17, 2008
Number of Results: 905
Database | Years Searched | Number of Results
CINAHL^®^ (Cumulative Index to Nursing & Allied Health Literature) | 1937 to 2008 | 280
SPORTDiscus with Full Text | 1800 to 2008 | 246
Academic Search Elite | 1985 to 2008 | 379
MULTIFILE STRATEGY
S1 | (DE “EXERCISE” OR DE “ABDOMINAL exercises” OR DE “AEROBIC exercises” OR DE “AQUATIC exercises” OR DE “ARM exercises” OR DE “BACK exercises” OR DE “BREATHING exercises” OR DE “BREEMA” OR DE “BUTTOCKS exercises” OR DE “CALLISTHENICS” OR DE “CHAIR exercises” OR DE “CIRCUIT training” OR DE “EXERCISE therapy” OR DE “FACIAL exercises” OR DE “FALUN gong exercises” OR DE “GYMNASTICS” OR DE “HAND exercises” OR DE “HATHA yoga” OR DE “ISOKINETIC exercise” OR DE “ISOMETRIC exercise” OR DE “LEG exercises” OR DE “LIANGONG” OR DE “METABOLIC equivalent” OR DE “MU-lan chuan” OR DE “MUSCLE strength” OR DE “PHYSICAL fitness” OR DE “PHYSICAL fitness for men” OR DE “PILATES method” OR DE “PLYOMETRICS” OR DE “QI gong” OR DE “REDUCING exercises” OR DE “RUNNING” OR DE “SCHOOLS -- Exercises & recreations” OR DE “SEXUAL exercises” OR DE “SHOULDER exercises” OR DE “STRETCHING exercises” OR DE “TAI chi chuan” OR DE “TREADMILL exercise”) or (DE “SPORTS” OR DE “AERONAUTICAL sports” OR DE “AGE & sports” OR DE “AQUATIC sports” OR DE “BALL games” OR DE “BASEBALL” OR DE “BASKETBALL” OR DE “CHARITY sports events” OR DE “COLLEGE sports” OR DE “DISCRIMINATION in sports” OR DE “DOPING in sports” OR DE “ENDURANCE sports” OR DE “EXTREME sports” OR DE “FASCISM & sports” OR DE “FEMINISM & sports” OR DE “FOOTBALL” OR DE “GAELIC games” OR DE “GAY Games” OR DE “GAYS & sports” OR DE “GLBT people & sports” OR DE “GLBT rodeos” OR DE “GOLF” OR DE “GOODWILL Games” OR DE “GROUP games” OR DE “GYMNASTICS” OR DE “HOCKEY” OR DE “HOMOPHOBIA in sports” OR DE “INDIVIDUAL sports” OR DE “KNIFE throwing” OR DE “LESBIANS & sports” OR DE “LOG-chopping (Sports)” OR DE “MASCULINITY in sports” OR DE “MASS media & sports” OR DE “MILITARY sports” OR DE “MINORITIES in sports” OR DE “MOTION pictures in sports” OR DE “MOTORSPORTS” OR DE “NATIONAL socialism & sports” OR DE “NATIONALISM & sports” OR DE “OLYMPICS” OR DE “PARKOUR” OR DE “PRESIDENTS -- Sports” OR DE “PRESIDENTS -- United States -- Sports” OR DE “PROFESSIONAL sports” OR DE “PROFESSIONALISM in sports” OR DE “RACING” OR DE “RACISM in sports” OR DE “RACKET games” OR DE “ROBOTICS in sports” OR DE “RODEOS” OR DE “ROLLER skating” OR DE “SCHOOL sports” OR DE “SENIOR Olympics” OR DE “SEX discrimination in sports” OR DE “SEXUAL harassment in sports” OR DE “SHOOTING” OR DE “SHUTOUTS (Sports)” OR DE “SOCCER” OR DE “SOCIALISM & sports” OR DE “SPORT for All” OR DE “SPORTS & tourism” OR DE “SPORTS -- Collectibles” OR DE “SPORTS -- Corrupt practices” OR DE “SPORTS -- Economic aspects” OR DE “SPORTS -- Finance” OR DE “SPORTS -- Songs & music” OR DE “SPORTS for children” OR DE “SPORTS for people with disabilities” OR DE “SPORTS for women” OR DE “SPORTS forecasting” OR DE “SPORTS rivalries” OR DE “SPORTS teams” OR DE “STEREOTYPES (Social psychology) in sports” OR DE “TARGETS (Sports)” OR DE “TEAMWORK (Sports)” OR DE “TELEVISION & sports” OR DE “TOMAHAWK throwing” OR DE “TRACEURS” OR DE “VIDEO tapes in sports” OR DE “VIOLENCE in sports” OR DE “WINTER sports”)
S2 | (MH “Sports+”) or (MH “Physical Fitness”) or (MH “Exercise+”)
S3 | exerc* OR train* OR fitness OR physical OR athlet* OR sport*
S4 | S3 or S2 or S1
S5 | (bronchial* OR respiratory OR airway* OR lung* ) and ( hypersensitiv* OR hyperreactiv* OR allerg* OR insufficiency )
S6 | bronchoconstrict* OR asthma* OR antiasthma* OR wheez* OR “Respiratory Sounds” OR “Bronchial Spasm” OR bronchospas* OR “Bronchial Hyperactivity” OR “Respiratory Hypersensitivity”
S7 | DE “BRONCHIAL spasm”
S8 | (MH “Bronchoconstriction”)
S9 | (MH “Asthma”)
S10 | (bronch* AND spasm* ) or ( bronch* AND constrict* )
S11 | S10 or S9 or S8 or S7 or S6 or S5
S12 | S11 and S4
S13 | DE “EXERCISE-induced asthma”
S14 | (MH “Asthma, Exercise-Induced”)
S15 | S14 or S13 or S12
S16 | diagnos* OR specificity OR accurac* OR predictive OR sensitiv* OR probability OR likelihood
S17 | S16 and S15
S18 | S16 and S15 Limiters - Exclude MEDLINE records; Language: English

Table B3 Diagnosis of EIB/EIA review – Web of Science^® -^ Institute for Scientific Information – Thomson Reuters

Years/issue searched: 1900 to 2008
Search date: November 17, 2008
Number of Results: 984
TS=((exerc* OR train* OR fitness OR “physical activity” OR athlet* OR sport*) AND (bronchoconstrict* OR asthma* OR antiasthma* OR wheez* OR “Respiratory Sounds” OR “Bronchial Spasm” OR bronchospas* OR “Bronchial Hyperreactivity” OR “Respiratory Hypersensitivity” OR (bronch* AND spasm*) OR (bronch* AND constrict*) OR (bronchial* OR respiratory OR airway* OR lung*) AND (hypersensitiv* OR hyperreactiv* OR allerg* OR insufficiency))) AND TS=(diagnos* OR sensitiv* or predictive OR accurac* OR specificity OR probability OR likelihood) AND Language=(English) AND Document Type=(Article OR Meeting Abstract OR Meeting-Abstract OR Proceedings Paper)

Table B4 Diagnosis of EIB/EIA review – BIOSIS PREVIEWS^® -^ Institute for Scientific Information – Thomson Reuters

Years/issue searched: 1926 to 2008
Search date: November 17, 2008
Number of Results: 1317
#1 Topic=(diagnos* OR sensitiv* or predictive OR accurac* OR specificity OR likelihood OR probability) #2 Topic=(exerc* OR train* OR fitness OR “physical activity” OR athlet* OR sport*) #3 TS=(bronchial* OR respiratory OR airway* OR lung*) SAME TS=(hypersensitiv* OR hyperreactiv* OR allerg* OR insufficiency) #4 TS=(bronchoconstrict* OR asthma* OR antiasthma* OR wheez* OR “Respiratory Sounds” OR “Bronchial Spasm” OR bronchospas* OR “Bronchial Hyperreactivity” OR “Respiratory Hypersensitivity” OR (bronch* SAME spasm*) OR (bronch* SAME constrict*)) #5 #3 OR #4 #6 #1 AND #2 AND #5 AND Language=(English) AND Document Type=(Article OR Book Chapter OR Meeting OR Meeting Paper OR Technical Report OR Thesis Dissertation) AND Taxa Notes=(Humans) #7 TI=COPD NOT TI=asthma* #8 #6 NOT #7

Table B5 Diagnosis of EIB/EIA review – PubMed: National Library of Medicine

Years/issue searched: 1950 to 2008
Search date: November 25, 2008
Number of Results: 138
(“diagnosis”[MeSH Subheading] OR diagnos* OR sensitiv* OR predictive OR accurac* OR specificity OR probability OR likelihood OR mannitol OR methacholine) AND ((((bronchoconstrict* OR asthma* OR antiasthma* OR wheez* OR “Respiratory Sounds” OR “Bronchial Spasm” OR bronchospas* OR “Bronchial Hyperreactivity” OR “Respiratory Hypersensitivity”) OR (bronch* AND (spasm* OR constrict*)) OR ((bronchial* OR respiratory OR airway* OR lung*) AND (hypersensitiv* OR hyperreactiv* OR allerg* OR insufficiency))) AND (exerc* OR train* OR fitness OR “physical activity” OR athlet* OR sport*)) OR ((EIB OR EIA) AND (asthma* OR bronch*))) Limits: added to PubMed in the last 1 year, English

Table B6 Diagnosis of EIB/EIA review – Scopus ^®^: Elsevier

Years/issue searched: 1823 to 2008
Search date: November 14, 2008
Number of Results: 1466
TITLE-ABS-KEY(diagnos* OR sensitiv* OR predictive OR accurac* OR specificity OR probability OR likelihood OR methacholine OR mannitol OR screen* OR test*) AND TITLE-ABS-KEY-AUTH(exercise induced asthma) AND (LIMIT-TO(LANGUAGE, “English”)) AND (LIMIT-TO(DOCTYPE, “ar”) OR LIMIT‐ TO(DOCTYPE, “cp”) OR LIMIT-TO(DOCTYPE, “ip”))

Table B7 Diagnosis of EIB/EIA review – Medion database of diagnostic reviews - University of Maastricht

Years/issue searched: 1967 to 2008
Search date: November 28, 2008
Number of Results: 0
Asthma, eia, eib, exercise

Table B8 Diagnosis of EIB/EIA review – Proquest Dissertations and Theses

Years/issue searched: 1861 to 2008
Search date: November 13, 2008
Number of Results: 25
(bronchoconstrict* OR asthma* OR antiasthma* OR wheez* OR “Respiratory Sounds” OR “Bronchial Spasm” OR bronchospas* OR “Bronchial Hyperreactivity” OR “Respiratory Hypersensitivity” OR (bronch* AND (spasm* OR constrict*))) AND TITLE(exerc* OR train* OR fitness OR “physical activity” OR athlet* OR sport*) AND (diagnos* OR sensitiv* OR predictive OR accurac* OR specificity OR probability OR likelihood OR methacholine OR mannitol OR EVH OR screen* OR test*) AND LN(EN)
Look for terms in: Citation and abstract
Publication type: All publication types

Table B9 Therapy for EIB/EIA review – Cochrane Airways Register

Years/issue searched: 1900 to 2008
Search date: November 5, 2008
Number of Results: 1601
The following databases are searched systematically for the Cochrane Airways Register: Cochrane Central Register of Controlled Trials (CENTRAL), MEDLINE, EMBASE, CINAHL, AMED and PsycINFO, and hand searching of respiratory journals and meeting abstracts.
(exerc* OR train* OR fitness OR physical OR athlete* OR sport*) AND (bronchoconstrict* OR asthma* OR antiasthma* OR wheez* OR “Respiratory Sounds” OR “Bronchial Spasm” OR bronchospas* OR “Bronchial Hyperreactivity” OR “Respiratory Hypersensitivity” OR (bronch* AND spasm*) OR (bronch* AND constrict*).OR (bronchial* OR respiratory OR airway* OR lung*) AND (hypersensitiv* OR hyperreactiv* OR allerg* OR insufficiency)) OR EIB OR EIA

Table B10 Therapy for EIB/EIA review – ClinicalTrials.Gov: National Institutes of Health

Search date: November 28, 2008
Number of Results: 31
asthma OR eia OR eib OR exercise-induced

Table B11 Therapy for EIB/EIA review – ClinicalStudyResults.Org: PhRMA Clinical Study Results Database

Search date: November 28, 2008
Number of Results: 2
Browsed by trade and generic drug names