# Technical Expert Panel and Peer Reviewers

## Technical Expert Panel

In designing the study questions and methodology, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicting opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Due to these differences in opinion, the study questions, design, and/or methodologic approaches do not necessarily represent the views of individual technical and content experts.

Technical Expert | Affiliations/Location
Louis-Philippe Boulet, M.D., F.R.C.P.C. | Université Laval and Hôpital Laval Sainte-Foy, QC
Robert Cowie, M.D., F.C.P.(S.A.), M.Sc. | University of Calgary Calgary, AB
Andrew Gregory, M.D., F.A.A.P., F.A.C.S.M. | Vanderbilt University Medical Center Nashville, TN
Cynthia LaBella, M.D. | Children’s Memorial Hospital Chicago, IL
Darcy Marciniuk, M.D., F.R.C.P.C. | University of Saskatchewan Saskatoon, SK
Kenneth Rundell, Ph.D. | Marywood University Scranton, PA

## Peer Reviewers

Peer reviewer comments on a preliminary draft of this report were considered by the EPC in preparation of the final report. The synthesis presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewer | Affiliations/Location
Louis-Philippe Boulet, M.D., F.R.C.P.(C.) | Université Laval and Hôpital Laval Sainte-Foy, QC
Robert Cowie, M.D., F.C.P.(S.A.), M.Sc. | University of Calgary Calgary, AB
Andrew Gregory, M.D., F.A.A.P., F.A.C.S.M. | Vanderbilt University Medical Center Nashville, TN
Kenneth Rundell, Ph.D. | Marywood University Scranton, PA
Jeannette May | Representative, Disease Management Association of America Washington, DC
H. William Kelly, Pharm.D. | University of New Mexico Albuquerque, NM
Sheldon Spector, M.D. & Ricardo Tan, M.D. | California Allergy & Asthma Medical Group Los Angeles, CA
John Weiler, M.D. | American Academy of Asthma Allergy and Immunology Iowa City, IA