# Appendixes

Appendix A Technical Expert Panel and Peer Reviewers

Appendix B Literature Search Strings

Appendix C Forms

Appendix D Excluded Studies

Appendix E Studies Investigating Mast Cell Stabilizing Agents