# Acknowledgments

We are grateful to members of the technical expert panel, Dr. Louis-Philippe Boulet (Université Laval, Sainte-Foy, QC), Dr. Robert Cowie (University of Calgary, AB), Dr. Andrew Gregory (Vanderbilt University Medical Center, Nashville, TN), Dr. Cynthia LaBella (Children’s Memorial Hospital, Chicago, IL), Dr. Darcy Marciniuk (University of Saskatoon, SK), Dr. Kenneth Rundell (Marywood University, Scranton, PA), Dr. John Weiler (American Academy of Asthma Allergy and Immunology) and Karen Siegel (Agency for Healthcare Research and Quality), who provided direction for the scope and content of the review. We thank the Cochrane Airways Group for their assistance and providing access to their database of articles. We also thank all the individuals at AHRQ, the Scientific Resource Center, and the peer reviewers for their comments and suggestions.

We thank Jennifer Seida for her work in developing the protocol, Mohammad Karkhaneh and Kate O’Gorman for assistance with data extraction and preparation of the appendices, Ken Bond for copyediting, and Simon Bow and Annabritt Chisholm for their assistance with literature retrieval.