# Abbreviations

95% CI: 95 percent confidence interval
ATS: American Thoracic Society
AUC: Area under the curve
BI: Bronchoprotection index
C: Centigrade
CCT: Clinical controlled trial
CO_2_: Carbon dioxide
ECT: Exercise challenge test
EIA: Exercise induced asthma
EIB: Exercise induced bronchoconstriction
EVH: Eucapnic voluntary hyperpnea
FEV_1_: Forced expiratory volume in 1 second
FRAST: Free running asthma screening test
GRADE: Grading of Recommendation, Assessment, Development, and Evaluation
IB: Ipratropium bromide
ICS: Inhaled corticosteroid
IPD: Individual patient data
IQR: Inter-quartile range
LABA: Long-acting beta-agonist
LTRA: Leukotriene receptor antagonist
MCH: Methacholine challenge
MCS: Mast cell stabilizer
MD: Mean difference
MDI: Metered-dose inhaler
Mg/ml: Milligrams per millilitre
Mg: Milligram
MVV: Maximum voluntary ventilation
NCS: Nedocromil sodium
NSAIDS: Nonsteroidal anti-inflammatory drugs
O_2_: Oxygen
OB: Oxitropium bromide
PC_20_: Provocative concentration causing a 20 percent fall in FEV_1_
PEF: Peak expiratory flow
QUADAS: Quality Assessment of Studies of Diagnostic Accuracy
RCT: Randomized controlled trial
RH: Relative humidity
ROC: Receiver operating characteristic
RR: Risk ratio
SAAC: Short-acting anticholinergic
SABA: Short-acting beta-agonist
SCG: Sodium cromoglycate
SD: Standard deviation
SE: Standard error
STARD: Standard of Reporting of Diagnostic Accuracy
TEP: Technical expert panel
VATAP: Veterans Affairs Technology Assessment
Program VO_2max_: Maximum oxygen consumption