# References and Included Studies

1 Eysenbach G. (2000). Consumer health informatics. BMJ.
2 Houston JD, Fiore DC. (1998). Online medical surveys: using the Internet as a research tool. MD Comput.
3 Berlin JA. (1997). Does blinding of readers affect the results of meta-analyses? University of Pennsylvania Meta-analysis Blinding Study Group. Lancet.
4 Jadad AR, Moore RA, Carroll D, et al. (1996). Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials.
5 Atkins D, Best D, Briss PA, et al. (2004). Grading quality of evidence and strength of recommendations. BMJ.
6 Methods Reference Manual for Comparative Effectiveness Reviews. The Agency for Healthcare Research and Quality, 2007.
7 Huss K, Salerno M, Huss RW. (1991). Computer-assisted reinforcement of instruction: effects on adherence in adult atopic asthmatics. Res Nurs Health.
8 Krishna S, Francisco BD, Balas EA, Konig P, Graff GR, Madsen RW. (2003). Internet-enabled interactive multimedia asthma education program: a randomized trial. Pediatrics.
9 Chewning B, Mosena P, Wilson D, et al. (1999). Evaluation of a computerized contraceptive decision aid for adolescent patients. Patient Educ Couns.
10 Jan RL, Wang JY, Huang MC, Tseng SM, Su HJ, Liu LF. (2007). An internet-based interactive telemonitoring system for improving childhood asthma outcomes in Taiwan. Telemed J E Health.
11 Guendelman S, Meade K, Benson M, Chen YQ, Samuels S. (2002). Improving asthma outcomes and self-management behaviors of inner-city children: A randomized trial of the Health Buddy interactive device and an asthma diary. Arch Pediatr Adolesc Med.
12 Bartholomew LK, Gold RS, Parcel GS, et al. (2000). Watch, Discover, Think, and Act: Evaluation of computer-assisted instruction to improve asthma self-management in inner-city children. Patient Educ Couns.
13 Gustafson DH, Hawkins R, Pingree S, et al. (2001). Effect of computer support on younger women with breast cancer. J Gen Intern Med.
14 Gustafson DH, Hawkins R, Mctavish F, et al. (2008). Internet-based interactive support for cancer patients: Are integrated systems better?. J Commun.
15 Jones R, Pearson J, McGregor S, et al. (1999). Randomised trial of personalised computer based information for cancer patients. BMJ.
16 Waterman AD, Banet G, Milligan PE, et al. (2001). Patient and physician satisfaction with a telephone-based anticoagulation service. J Gen Intern Med.
17 Adachi Y, Sato C, Yamatsu K, Ito S, Adachi K, Yamagami T. (2007). A randomized controlled trial on the long-term effects of a 1-month behavioral weight control program assisted by computer tailored advice. Behav Res Ther.
18 Anderson ES, Winett RA, Wojcik JR, Winett SG, Bowden T. (2001). A computerized social cognitive intervention for nutrition behavior: Direct and mediated effects on fat, fiber, fruits, and vegetables, self-efficacy, and outcome expectations among food shoppers. Ann Behav Med.
19 Brug J, Steenhuis I, Van Assema P, De Vries H. (1996). The impact of a computer-tailored nutrition intervention. Prev Med.
20 Brug J, Glanz K, Van Assema P, Kok G, Van Breukelen GJP. (1998). The Impact of Computer-Tailored Feedback and Iterative Feedback on Fat, Fruit, and Vegetable Intake. Health Educ Behav. Health Educ Behav.
21 Brug J, Steenhuis I, Van Assema P, Glanz K, De Vries H. (1999). Computer-tailored nutrition education: Differences between two interventions. PMID.
22 Campbell MK, DeVellis BM, Strecher VJ, Ammerman AS, DeVellis RF, Sandler RS. (1994). Improving dietary behavior: The effectiveness of tailored messages in primary care settings. Am J Public Health.
23 Campbell MK, Honess-Morreale L, Farrell D, Carbone E, Brasure M. (1999). A tailored multimedia nutrition education pilot program for low-income women receiving food assistance. Health Educ Res.
24 Campbell MK, Carbone E, Honess-Morreale L, Heisler-MacKinnon J, Demissie S, Farrell D. (2004). Randomized trial of a tailored nutrition education CD-ROM program for women receiving food assistance. J Nutr Educ Behav.
25 Haerens L, De Bourdeaudhuij I, Maes L, Vereecken C, Brug J, Deforche B. (2007). The effects of a middle-school healthy eating intervention on adolescents' fat and fruit intake and soft drinks consumption. Public Health Nutr.
26 Haerens L, Deforche B, Maes L, Brug J, Vandelanotte C, De Bourdeaudhuij I. (2007). A computer-tailored dietary fat intake intervention for adolescents: results of a randomized controlled trial. Ann Behav Med.
27 Haerens L, Maes L, Vereecken C, De Henauw S, Moreno L, De Bourdeaudhuij I. Effectiveness of a computer tailored physical activity intervention in adolescents compared to a generic advice. Patient Educ Couns 2009.
28 Hurling R, Fairley BW, Dias MB. (2006). Internet-based exercise intervention systems: Are more interactive designs better?. Psychology & Health.
29 Hurling R, Catt M, Boni MD, et al. (2007). Using internet and mobile phone technology to deliver an automated physical activity program: randomized controlled trial. J Med Internet Res.
30 Jones M, Luce KH, Osborne MI, et al. (2008). Randomized, controlled trial of an internet-facilitated intervention for reducing binge eating and overweight in adolescents. Pediatrics.
31 King DK, Estabrooks PA, Strycker LA, Toobert DJ, Bull SS, Glasgow RE. (2006). Outcomes of a multifaceted physical activity regimen as part of a diabetes self-management intervention. Ann Behav Med.
32 Kristal AR, Curry SJ, Shattuck AL, Feng Z, Li S. (2000). A randomized trial of a tailored, self-help dietary intervention: The Puget Sound Eating Patterns study. Prev Med.
33 Lewis B, Williams D, Dunsiger S, et al. (2008). User attitudes towards physical activity websites in a randomized controlled trial. Prev Med.
34 Low KG, Charanasomboon S, Lesser J, et al. (2006). Effectiveness of a computer-based interactive eating disorders prevention program at long-term follow-up. Eat Disord.
35 Marcus BH, Lewis BA, Williams DM, et al. (2007). A comparison of Internet and print-based physical activity interventions. Arch Intern Med.
36 Mangunkusumo R, Brug J, Duisterhout J, de Koning H, Raat H. (2007). Feasibility, acceptability, and quality of Internet-administered adolescent health promotion in a preventive-care setting. Health Educ Res.
37 Napolitano MA, Fotheringham M, Tate D, et al. (2003). Evaluation of an internet-based physical activity intervention: a preliminary investigation. Ann Behav Med.
38 Oenema A, Brug J, Lechner L. (2001). Web-based tailored nutrition education: results of a randomized controlled trial. Health Educ Res.
39 Richardson CR, Mehari KS, McIntyre LG, et al. (2007). A randomized trial comparing structured and lifestyle goals in an internet-mediated walking program for people with type 2 diabetes. Int J Behav Nutr Phys Act.
40 Silk KJ, Sherry J, Winn B, Keesecker N, Horodynski MA, Sayir A. (2008). Increasing nutrition literacy: testing the effectiveness of print, web site, and game modalities. J Nutr Educ Behav.
41 Smeets T, Kremers SP, Brug J, de Vries H. (2007). Effects of tailored feedback on multiple health behaviors. Ann Behav Med.
42 Spittaels H, De Bourdeaudhuij I, Brug J, Vandelanotte C. (2007). Effectiveness of an online computer-tailored physical activity intervention in a real-life setting. Health Educ Res.
43 Spittaels H, De Bourdeaudhuij I, Vandelanotte C. (2007). Evaluation of a website-delivered computer-tailored intervention for increasing physical activity in the general population. Prev Med.
44 Tate DF, Jackvony EH, Wing RR. (2006). A randomized trial comparing human e-mail counseling, computer-automated tailored counseling, and no counseling in an Internet weight loss program. Arch Intern Med.
45 Vandelanotte C, De Bourdeaudhuij I, Sallis JF, Spittaels H, Brug J. (2005). Efficacy of sequential or simultaneous interactive computer-tailored interventions for increasing physical activity and decreasing fat intake. Ann Behav Med.
46 Verheijden M, Bakx JC, Akkermans R, et al. (2004). Web-based targeted nutrition counselling and social support for patients at increased cardiovascular risk in general practice: randomized controlled trial. J Med Internet Res.
47 Winzelberg AJ, Eppstein D, Eldredge KL, et al. (2000). Effectiveness of an Internet-based program for reducing risk factors for eating disorders. J Consult Clin Psychol.
48 Wylie-Rosett J, Swencionis C, Ginsberg M, et al. (2001). Computerized weight loss intervention optimizes staff time: The clinical and cost results of a controlled clinical trial conducted in a managed care setting. J Am Diet Assoc.
49 National Center for Health Statistics. National Health and Nutrition Examination Survey [Web Page]. Available at http://www.cdc.gov/nchs/about/major/nhanes/growthcharts/GrowthchartFAQs.htm
50 Doumas DM, Hannah E. (2008). Preventing high-risk drinking in youth in the workplace: a web-based normative feedback program. J Subst Abuse Treat.
51 Kypri K, Saunders JB, Williams SM, et al. (2004). Web-based screening and brief intervention for hazardous drinking: a double-blind randomized controlled trial. Addiction.
52 Neighbors C, Larimer ME, Lewis MA. (2004). Targeting misperceptions of descriptive drinking norms: efficacy of a computer-delivered personalized normative feedback intervention. J Consult Clin Psychol.
53 An LC, Klatt C, Perry CL, et al. (2008). The RealU online cessation intervention for college smokers: a randomized controlled trial. Prev Med.
54 Patten CA, Croghan IT, Meis TM, et al. (2006). Randomized clinical trial of an Internet-based versus brief office intervention for adolescent smoking cessation. Patient Educ Couns.
55 Cunningham JA, Humphreys K, Koski-Jannes A, Cordingley J. (2005). Internet and paper self-help materials for problem drinking: is there an additive effect?. Addict Behav.
56 Hester RK, Squires DD, Delaney HD. (2005). The Drinker's Check-up: 12-month outcomes of a controlled clinical trial of a stand-alone software program for problem drinkers. J Subst Abuse Treat.
57 Lieberman DZ. (2006). Effects of a personified guide on adherence to an online program for alcohol abusers. Cyberpsychol Behav.
58 Riper H, Kramer J, Smit F, Conijn B, Schippers G, Cuijpers P. (2008). Web-based self-help for problem drinkers: a pragmatic randomized trial. Addiction.
59 Riper H, Kramer J, Keuken M, Smit F, Schippers G, Cuijpers P. (2008). Predicting successful treatment outcome of web-based self-help for problem drinkers: secondary analysis from a randomized controlled trial. J Med Internet Res.
60 Brendryen H, Drozd F, Kraft P. (2008). A digital smoking cessation program delivered through internet and cell phone without nicotine replacement (happy ending): randomized controlled trial. J Med Internet Res.
61 Curry SJ, McBride C, Grothaus LC, Louie D, Wagner EH. (1995). A randomized trial of self-help materials, personalized feedback, and telephone counseling with nonvolunteer smokers. J Consult Clin Psychol.
62 Dijkstra A. (2005). Working mechanisms of computer-tailored health education: Evidence from smoking cessation. Health Educ Res.
63 Haug S, Meyer C, Schorr G, Bauer S, John U. Continuous individual support of smoking cessation using text messaging: A pilot experimental study. Nicotine Tob Res 2009.
64 Japuntich SJ, Zehner ME, Smith SS, et al. (2006). Smoking cessation via the internet: a randomized clinical trial of an internet intervention as adjuvant treatment in a smoking cessation intervention. Nicotine Tob Res.
65 Prochaska JO, DiClemente CC, Velicer WF, Rossi JS. (1993). Standardized, Individualized, Interactive, and Personalized Self-Help Programs for Smoking Cessation. Health Psychol.
66 Prokhorov AV, Kelder SH, Shegog R, et al. (2008). Impact of A Smoking Prevention Interactive Experience (ASPIRE), an interactive, multimedia smoking prevention and cessation curriculum for culturally diverse high-school students. Nicotine Tob Res.
67 Severson HH, Gordon JS, Danaher BG, Akers L. (2008). ChewFree.com: evaluation of a Web-based cessation program for smokeless tobacco users. Nicotine Tob Res.
68 Shiffman S, Paty JA, Rohay JM, Di Marino ME, Gitchell J. (2000). The efficacy of computer-tailored smoking cessation material as a supplement to nicotine polacrilex gum therapy. Arch Intern Med.
69 Schumann A, John U, Rumpf H-J, Hapke U, Meyer C. (2006). Changes in the "stages of change" as outcome measures of a smoking cessation intervention: A randomized controlled trial. Prev Med.
70 Schumann A, John U, Baumeister SE, Ulbricht S, Rumpf HJ, Meyer C. (2008). Computer-tailored smoking cessation intervention in a general population setting in Germany: outcome of a randomized controlled trial. Nicotine Tob Res.
71 Strecher VJ, McClure JB, Alexander GL, et al. (2008). Web-based smoking-cessation programs: results of a randomized trial. Am J Prev Med.
72 Strecher VJ, Shiffman S, West R. (2006). Moderators and mediators of a web-based computer-tailored smoking cessation program among nicotine patch users. Nicotine Tob Res.
73 Strecher VJ, Marcus A, Bishop K, et al. (2005). A randomized controlled trial of multiple tailored messages for smoking cessation among callers to the cancer information service. J Health Commun.
74 Strecher VJ, Shiffman S, West R. (2005). Randomized controlled trial of a web-based computer-tailored smoking cessation program as a supplement to nicotine patch therapy. Addiction.
75 Strecher VJ, Kreuter M, Den Boer D-J, Kobrin S, Hospers HJ, Skinner CS. (1994). The effects of computer-tailored smoking cessation messages in family practice settings. J Fam Pract.
76 Swartz LH, Noell JW, Schroeder SW, Ary DV. (2006). A randomised control study of a fully automated internet based smoking cessation programme. Tob Control.
77 Reach G. Obstacles to patient education in chronic diseases: A trans-theoretical analysis. Patient Educ Couns 2009.
78 Schneider SJ, Walter R, O'Donnell R. (1990). Computerized communication as a medium for behavioral smoking cessation treatment: Controlled evaluation. Computers in Human Behavior.
79 Weinstein ND. (1988). The precaution adoption process. Health Psychol.
80 Kroeze W, Oenema A, Campbell M, Brug J. (2008). The efficacy of Web-based and print-delivered computer-tailored interventions to reduce fat intake: results of a randomized, controlled trial. J Nutr Educ Behav.
81 McConnon A, Kirk SF, Cockroft JE, et al. (2007). The Internet for weight control in an obese sample: results of a randomised controlled trial. BMC Health Serv Res.
82 Epstein LH, Valoski A, Wing RR, McCurley J. (1994). Ten-year outcomes of behavioral family-based treatment for childhood obesity. Health Psychol.
83 Williamson DA, Walden HM, White MA, et al. (2006). Two-year internet-based randomized controlled trial for weight loss in African-American girls. Obesity (Silver Spring).
84 Womble LG, Wadden TA, McGuckin BG, Sargent SL, Rothman RA, Krauthamer-Ewing ES. (2004). A randomized controlled trial of a commercial internet weight loss program. Obes Res.
85 Hunter CM, Peterson AL, Alvarez LM, et al. (2008). Weight management using the internet a randomized controlled trial. Am J Prev Med.
86 Cussler EC, Teixeira PJ, Going SB, et al. (2008). Maintenance of weight loss in overweight middle-aged women through the Internet. Obesity (Silver Spring).
87 Booth AO, Nowson CA, Matters H. (2008). Evaluation of an interactive, Internet-based weight loss program: a pilot study. Health Educ Res.
88 Frenn M, Malin S, Brown RL, et al. (2005). Changing the tide: An Internet/video exercise and low-fat diet intervention with middle-school students. Appl Nurs Res.
89 Taylor CB, Agras WS, Losch M, Plante TG, Burnett K. (1991). Improving the effectiveness of computer-assisted weight loss. Behavior Therapy.
90 Burnett KF, Taylor CB, Agras WS. (1985). Ambulatory computer-assisted therapy for obesity: A new frontier for behavior therapy. J Consult Clin Psychol.
91 Morgan PJ, Lubans DR, Collins CE, Warren JM, Callister R. The SHED-IT Randomized Controlled Trial: Evaluation of an Internet-based Weight-loss Program for Men. Obesity (Silver Spring) 2009.
92 Homko CJ, Santamore WP, Whiteman V, et al. (2007). Use of an internet-based telemedicine system to manage underserved women with gestational diabetes mellitus. Diabetes Technol Ther.
93 Wangberg SC. (2008). An Internet-based diabetes self-care intervention tailored to self-efficacy. Health Educ Res.
94 Wise PH, Dowlatshahi DC, Farrant S. (1986). Effect of computer-based learning on diabetes knowledge and control. Diabetes Care.
95 McKay HG, King D, Eakin EG, Seeley JR, Glasgow RE. (2001). The diabetes network internet-based physical activity intervention: a randomized pilot study. Diabetes Care.
96 Lorig KR, Ritter PL, Laurent DD, Plant K. (2006). Internet-based chronic disease self-management: a randomized trial. Med Care.
97 Glasgow RE, Boles SM, McKay HG, Feil EG, Barrera M. (2003). The D-Net diabetes self-management program: long-term implementation, outcomes, and generalization results. Prev Med.
98 Proudfoot J, Ryden C, Everitt B, et al. (2004). Clinical efficacy of computerised cognitive-behavioural therapy for anxiety and depression in primary care: randomised controlled trial. Br J Psychiatry.
99 Christensen H, Griffiths KM, Jorm AF. (2004). Delivering interventions for depression by using the internet: randomised controlled trial. BMJ.
100 Hasson D, Anderberg UM, Theorell T, Arnetz BB. (2005). Psychophysiological effects of a web-based stress management system: a prospective, randomized controlled intervention study of IT and media workers. BMC Public Health.
101 Chiauzzi E, Brevard J, Thurn C, Decembrele S, Lord S. (2008). MyStudentBody-Stress: an online stress management intervention for college students. J Health Commun.
102 Schneider AJ, Mataix-Cols D, Marks IM, Bachofen M. (2005). Internet-guided self-help with or without exposure therapy for phobic and panic disorders. Psychother Psychosom.
103 Fathelrahman AI, Omar M, Awang R, et al. (2009). Smokers' responses toward cigarette pack warning labels in predicting quit intention, stage of change, and self-efficacy. Nicotine Tob Res.
104 Glasheen JJ, Cumbler EU. (2009). Tailoring internal medicine training to improve hospitalist outcomes. Arch Intern Med.
105 Zetterqvist K, Maanmies J, Ström L, Andersson G. (2003). Randomized controlled trial of internet-based stress management. Cogn Behav Ther.
106 Neil AL, Batterham P, Christensen H, Bennett K, Griffiths KM. (2009). Predictors of adherence by adolescents to a cognitive behavior therapy website in school and community-based settings. J Med Internet Res.
107 Warmerdam L, van Straten A, Twisk J, Riper H, Cuijpers P. (2008). Internet-based treatment for adults with depressive symptoms: randomized controlled trial. J Med Internet Res.
108 Simon SR, Soumerai SB. (2005). Failure of Internet-based audit and feedback to improve quality of care delivered by primary care residents. Int J Qual Health Care.
109 Joseph CL, Peterson E, Havstad S, et al. (2007). A web-based, tailored asthma management program for urban African-American high school students. Am J Respir Crit Care Med.
110 Nguyen HQ, Donesky-Cuenco D, Wolpin S, et al. (2008). Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res.
111 Franck L, Noble G, McEvoy M. (2008). Enquiring minds want to know: topics requested by users of a children's health information website. Patient Educ Couns.
112 Kukafka R, Lussier YA, Eng P, Patel VL, Cimino JJ. Web-based tailoring and its effect on self-efficacy: results from the MI-HEART randomized controlled trial. Proc AMIA Symp 2002; 410-4.
113 Chumley HS, Dobbie AE, Delzell JE. (2006). Case-based exercises fail to improve medical students' information management skills: a controlled trial. BMC Med Educ.
114 Lorig KR, Ritter PL, Laurent DD, Plant K. (2008). The internet-based arthritis self-management program: a one-year randomized trial for patients with arthritis or fibromyalgia. Arthritis Rheum.
115 Buhrman M, Faltenhag S, Strom L, Andersson G. (2004). Controlled trial of Internet-based treatment with telephone support for chronic back pain. Pain.
116 Oenema A, Brug J, Dijkstra A, de Weerdt I, de Vries H. (2008). Efficacy and use of an internet-delivered computer-tailored lifestyle intervention, targeting saturated fat intake, physical activity and smoking cessation: a randomized controlled trial. Ann Behav Med.
117 Campbell E, Peterkin D, Abbott R, Rogers J. (1997). Encouraging underscreened women to have cervical cancer screening: the effectiveness of a computer strategy. Prev Med.
118 Brennan PF, Moore SM, Smyth KA. (1995). The effects of a special computer network on caregivers of persons with Alzheimer's disease. Nurs Res.
119 Harari D, Iliffe S, Kharicha K, et al. (2008). Promotion of health in older people: a randomised controlled trial of health risk appraisal in British general practice. Age Ageing.
120 Devineni T, Blanchard EB. (2005). A randomized controlled trial of an internet-based treatment for chronic headache. Behav Res Ther.
121 Flatley-Brennan P. (1998). Computer network home care demonstration: a randomized trial in persons living with AIDS. Comput Biol Med.
122 Schapira MM, Gilligan MA, McAuliffe T, Garmon G, Carnes M, Nattinger AB. (2007). Decision-making at menopause: a randomized controlled trial of a computer-based hormone therapy decision-aid. Patient Educ Couns.
123 Rostom A, O'Connor A, Tugwell P, Wells G. (2002). A randomized trial of a computerized versus an audio-booklet decision aid for women considering post-menopausal hormone replacement therapy. Patient Educ Couns.
124 Yardley L, Nyman SR. (2007). Internet provision of tailored advice on falls prevention activities for older people: a randomized controlled evaluation. Health Promot Int.
125 Paperny DM, Aono JY, Lehman RM, Hammar SL, Risser J. (1990). Computer-assisted detection and intervention in adolescent high-risk health behaviors. J Pediatr.
126 Simkins CV, Wenzloff NJ. (1986). Evaluation of a computerized reminder system in the enhancement of patient medication refill compliance. Drug Intell Clin Pharm.
127 James N, Daniels H, Rahman R, McConkey C, Derry J, Young A. (2007). A study of information seeking by cancer patients and their carers. Clin Oncol (R Coll Radiol).
128 Green MJ, Peterson SK, Baker MW, et al. (2005). Use of an educational computer program before genetic counseling for breast cancer susceptibility: effects on duration and content of counseling sessions. Genet Med.
129 Maslin AM, Baum M, Walker JS, A'Hern R, Prouse A. (1998). Using an interactive video disk in breast cancer patient support. Nurs Times.
130 Montgomery AA, Emmett CL, Fahey T, et al. (2007). Two decision aids for mode of delivery among women with previous caesarean section: randomised controlled trial. BMJ.
131 Sciamanna CN, Harrold LR, Manocchia M, Walker NJ, Mui S. (2005). The effect of web-based, personalized, osteoarthritis quality improvement feedback on patient satisfaction with osteoarthritis care. Am J Med Qual.
132 Tjam EY, Sherifali D, Steinacher N, Hett S. (2006). Physiological outcomes of an internet disease management program vs. in-person counselling: A randomized, controlled trial. Candian Journal of Diabetes.
133 Orbach G, Lindsay S, Grey S. (2007). A randomised placebo-controlled trial of a self-help Internet-based intervention for test anxiety. Behav Res Ther.
134 March S, Spence SH, Donovan CL. The Efficacy of an Internet-Based Cognitive-Behavioral Therapy Intervention for Child Anxiety Disorders. J Pediatr Psychol 2008.
135 Kerr J, Patrick K, Norman G, et al. (2008). Randomized control trial of a behavioral intervention for overweight women: impact on depressive symptoms. Depress Anxiety.
136 Spek V, Cuijpers P, Nyklicek I, et al. (2008). One-year follow-up results of a randomized controlled clinical trial on internet-based cognitive behavioural therapy for subthreshold depression in people over 50 years. Psychol Med.
137 Proudfoot J, Goldberg D, Mann A, Everitt B, Marks I, Gray JA. (2003). Computerized, interactive, multimedia cognitive-behavioural program for anxiety and depression in general practice. Psychol Med.
138 . Consolidated Standards of Reporting Trials (CONSORT) [Web Page]. Available at http://www.consort-statement.org/
139 Tarraga L, Boada M, Modinos G, et al. (2006). A randomised pilot study to assess the efficacy of an interactive, multimedia tool of cognitive stimulation in Alzheimer's disease. J Neurol Neurosurg Psychiatry.
140 Katz RC, Wertz RT. (1997). The efficacy of computer-provided reading treatment for chronic aphasic adults. J Speech Lang Hear Res.
141 Trautmann E, Kröner-Herwig B. (2008). Internet-based self-help training for children and adolescents with recurrent headache: A pilot study. Behavioural and Cognitive Psychotherapy.
142 Gustafson DH, Hawkins R, Boberg E, et al. (1999). Impact of a patient-centered, computer-based health information/support system. Am J Prev Med.
143 Borckardt JJ, Younger J, Winkel J, Nash MR, Shaw D. (2004). The computer-assisted cognitive/imagery system for use in the management of pain. Pain Res Manag.
144 Simon C, Acheson L, Burant C, et al. (2008). Patient interest in recording family histories of cancer via the Internet. Genet Med.
145 Paperny DM. (1997). Computerized health assessment and education for adolescent HIV and STD prevention in health care settings and schools. Health Educ Behav.
146 Shaw BR, Dubenske LL, Han JY, et al. (2008). Antecedent characteristics of online cancer information seeking among rural breast cancer patients: an application of the Cognitive-Social Health Information Processing (C-SHIP) model. J Health Commun.
147 Owen JE, Klapow JC, Roth DL, Nabell L, Tucker DC. (2004). Improving the effectiveness of adjuvant psychological treatment for women with breast cancer: the feasibility of providing online support. Psychooncology.
148 McTavish FM, Gustafson DH, Owens BH, et al. (1994). CHESS: An interactive computer system for women with breast cancer piloted with an under-served population. Proc Annu Symp Comput Appl Med Care.
149 Stock SE, Davies DK, Davies KR, Wehmeyer ML. (2006). Evaluation of an application for making palmtop computers accessible to individuals with intellectual disabilities. J Intellect Dev Disabil.
150 Weber B, Fritze J, Schneider B, Simminger D, Maurer K. Computerized self-assessment in psychiatric in-patients: acceptability, feasibility and influence of computer attitude. Acta Psychiatr Scand 1998; (2):140-5.
151 Zeman L, Johnson D, Arfken C, Smith T, Opoku P. (2006). Lessons learned: challenges implementing a personal digital assistant (PDA) to assess behavioral health in primary care. Families, Systems & Health. The Journal of Collaborative Family HealthCare.
152 Morak J, Schindler K, Goerzer E, et al. (2008). A pilot study of mobile phone-based therapy for obese patients. J Telemed Telecare.
153 Steele R, Mummery KW, Dwyer T. (2007). Development and process evaluation of an internet-based physical activity behaviour change program. Patient Educ Couns.
154 Ferney SL, Marshall AL. (2006). Website physical activity interventions: preferences of potential users. Health Educ Res.
155 Cavan DA, Everett J, Plougmann S, Hejlesen OK. Use of the Internet to optimize self-management of type 1 diabetes: preliminary experience with DiasNet. 2003; 9 Suppl 1.
156 Feil EG, Glasgow RE, Boles S, McKay HG. (2000). Who participates in internet-based self-management programs? A study among novice computer users in a primary care setting. Diabetes Educ.
157 Temesgen Z, Knappe-Langworthy JE, St Marie MM, Smith BA, Dierkhising RA. (2006). Comprehensive Health Enhancement Support System (CHESS) for people with HIV infection. AIDS Behav.
158 Jenkinson J, Wilson-Pauwels L, Jewett MA, Woolridge N. (1998). Development of a hypermedia program designed to assist patients with localized prostate cancer in making treatment decisions. J Biocommun.
159 Lahdenpera TS, Kyngas HA. (2000). Patients' views about information technology in the treatment of hypertension. J Telemed Telecare.
160 Cimino JJ, Patel VL, Kushniruk AW. (2001). What do patients do with access to their medical records?. Stud Health Technol Inform.
161 Keselman A, Slaughter L, Smith CA et al. Towards consumer-friendly PHRs: patients' experience with reviewing their health records. AMIA Annu Symp Proc 2007; 399-403.
162 Lober WB, Zierler B, Herbaugh A et al. Barriers to the use of a personal health record by an elderly population. AMIA Annu Symp Proc 2006; 514-8.
163 Nijland N, van Gemert-Pijnen J, Boer H, Steehouder MF, Seydel ER. (2008). Evaluation of internet-based technology for supporting self-care: problems encountered by patients and caregivers when using self-care applications. J Med Internet Res.
164 Shaw MJ, Beebe TJ, Tomshine PA, Adlis SA, Cass OW. (2001). A randomized, controlled trial of interactive, multimedia software for patient colonoscopy education. J Clin Gastroenterol.
165 Ferrer-Roca O, Cárdenas A, Diaz-Cardama A, Pulido P. (2004). Mobile phone text messaging in the management of diabetes. J Telemed Telecare.
166 Bryce CL, Zickmund S, Hess R, et al. (2008). Value versus user fees: perspectives of patients before and after using a web-based portal for management of diabetes. Telemed J E Health.
167 Boberg EW, Gustafson DH, Hawkins RP, et al. (1995). Development, acceptance, and use patterns of a computer-based education and social support system for people living with AIDS/HIV infection. Computers in Human Behavior.
168 Kressig RW, Echt KV. (2002). Exercise prescribing: Computer application in older adults. The Gerontologist.
169 Lenert L, Muñoz RF, Stoddard J, et al. (2003). Design and pilot evaluation of an internet smoking cessation program. J Am Med Inform Assoc.
170 Gibbons MC. (2005). A historical overview of health disparities and the potential of eHealth solutions. J Med Internet Res.
171 Christakis DA. Internet based patient-centered asthma management system (Project Status - Ongoing 2010), National Heart, Lung and Blood Institute, R01HL079402-01A2.
172 Brennan P, Downs S. Health Design; Rethinking the power and potential of Personal Health Records, Round One Final Report 2009. 2009.
173 Gibbons M, Edited by Michael Christopher Gibbons, MD, MPH. eHealth Solutions for Healthcare Disparities. NY: Springer, 2008.
174 Lorig KR. Internet diabetes self management evaluation (project status - completed 2008), National Institute of Diabetes and Digestive and Kidney Disease.
175 Col NF. Menopause Interactive Decision Aid System (project status - completed 2005). Agency for Healthcare Research and Quality.
176 Sciamanna CN. Computerized physical activity promotion in primary care - II (project status-completed 2008), National Heart, Lung, and Blood Institute.