# Acknowledgments

The EPC thanks Dr. Hosne Begum, Dr. Olaide Odelola, Dr. Christine Chang, Beth Barnett, Todd Noletto, and Rebecca Stainman for their assistance with the final assembly and formatting of this report, and Dr. Teresa Zayas-Cabán for her valuable insight throughout the project.