# 3 Results

## Results of the Literature Search

The literature search process identified 24,794 citations that were deemed potentially relevant to Key Questions 1 and/or 2 (see Figure 2) and 6673 additional articles were identified through hand searching, as described in Chapter 2. We identified no additional eligible articles in the grey literature. We excluded 8943 duplicate citations from the electronic search results. Most duplicates came from concurrently searching MEDLINE^®^, The Cochrane Library, EMBASE^®^, CINAHL, and SCOPUS. The search strategy used in all search engines was modeled on that which we used in MEDLINE^®^, with similar search terms (see Appendix C1). Additionally, the EMBASE^®^ search engine allows the user to search the MEDLINE^®^ database as well as EMBASE^®^, a strategy that often yields many duplicates between the two search sites. Our EPC employs this strategy to improve the sensitivity of the search.

Figure 2

Summary of literature search (number of articles)

In the title review process, we excluded 19,377 citations that clearly did not apply to the Key Questions. In the abstract review process, we excluded 2642 citations that did not meet one or more of the eligibility criteria (see Chapter 2 for details). At the article review phase, we excluded an additional 340 articles that did not meet one or more of the eligibility criteria (for a detailed list see Appendix F, list of excluded articles). Two more articles were removed from the pool of articles identified through the electronic databases at this stage due to difficulty in retrieving the article (Figure 2). Details on the grey literature search are available in Appendix D. The Johns Hopkins University Welch Library works with other libraries to ensure that University faculty and employees have access to nearly all published articles. Periodically, an article cannot be located through any of the cooperating libraries, and the EPC team goes directly to the authors to obtain the article — this was not possible for these two articles. Ultimately we were left with 162 articles that were eligible for inclusion in this report: One hundred thirty-seven for Key Question 1 and 31 for Key Question 2; six articles were eligible for both Key Question 1 and Key Question 2.

## Description of the Types of Studies Retrieved

One hundred thirty-seven studies applied to Key Question 1. The EPC team along with the TEP and AHRQ agreed that the best evidence available to measure outcomes of the impact of CHI applications on consumers would be found in randomized controlled trials (RCTs). Therefore, all of the Key Question 1 eligible studies were RCTs. The above group agreed that all study designs should be included when searching for and including articles investigating barriers to the use of CHI applications. The 31 articles addressing barriers to use of CHI applications fell under a variety of study designs and data collection types. Data on barriers was collected most commonly in non-validated surveys (24) or qualitative studies (7).

## Key Question 1a: What evidence exists that consumer health informatics applications impact health care process outcomes?

### Summary of the Findings

Very few studies evaluated the impact of CHI applications on health care processes (Table 1). Measures included monitoring and therapeutic adherence, and health care utilization. The quality of these trials was variable, ranging from moderate to very low, as measured by the Jadad4 criteria for RCT quality (Appendix F, Evidence Table 1). Postintervention followup duration varied from 12 weeks up to 1 year. The study results suggested a positive effect of CHI applications on monitoring and therapeutic adherence, and health care utilization.

Table 1

Summary of studies of CHI applications impacting health care process outcomes (N=5).

Target condition | N | Author, year | Interventions | Primary outcomes measured | Effect of CHI application^*^
Asthma | 4 | Bartholomew, 2000^12^ | Watch, Discover, Think and Act (An Interactive multimedia application on CD-ROM) | Enhancement of self-management skills | 0
Asthma | 4 | Guendelman, 2002^11^ | Health Buddy(person al and interactive communication device) | Health and quality of life and process evaluation | +
Asthma | 4 | Jan, 2007^10^ | Asthma education and an interactive asthma monitoring system | Monitoring adherence | +
Asthma | 4 | Jan, 2007^10^ | Asthma education and an interactive asthma monitoring system | Therapeutic adherence | −
Asthma | 4 | Jan, 2007^10^ | Asthma education and an interactive asthma monitoring system | Adherence to daily diary entry | +
Asthma | 4 | Jan, 2007^10^ | Asthma education and an interactive asthma monitoring system | Therapeutic adherence: dry powder inhaler (DPI) or metered dose inhaler (MDI) plus spacer technique score | +
Asthma | 4 | Jan, 2007^10^ | Asthma education and an interactive asthma monitoring system | Peak flow meter technique score | −
Asthma | 4 | Krishna,2003^8^ | Internet-enabled asthma education program | Days of quick relief medicine | +
Asthma | 4 | Krishna,2003^8^ | Internet-enabled asthma education program | Urgent physician visit | +
Asthma | 4 | Krishna,2003^8^ | Internet-enabled asthma education program | Emergency room visit | +
Oral contraceptive use | 1 | Chewning, 1999^9^ | Computerized decision aid | Oral contraceptive efficacy Chicago | 0
Oral contraceptive use | 1 | Chewning, 1999^9^ | Computerized decision aid | Oral contraceptive efficacy Madison | 0

* (+) positive impact of the CHI application on outcome; (−) negative impact of the CHI application on outcome; (0) no impact or not a significant of the CHI application on outcome

DPI=dry powder inhaler; MDI=metered dose inhaler

### Strengths and Limitations of the Evidence

Five studies assessed the impact of CHI applications on health care process outcomes in asthma, and another on the process outcome of contraceptive medication use. The asthma studies enrolled from 52^7^ to 228^8^ patients. The sample size in the contraception study was 949 (Appendix G, Evidence Tables 2–4).9 The overall strength of the body of the evidence from the asthma studies was graded as moderate (Table 2) based on a modified version of the GRADE criteria”5 and Chapter 11 of the EPC Manual6

Table 2

Grade of the body of evidence addressing CHI impact on health care processes in asthma.

1 | Protection against risk of bias (relates to study design, study quality, reporting bias) | High
2 | Number of studies | 4
3 | Did the studies have important inconsistency? y (−1); n (0) | 0
4 | Was there some (−1) or major (−2) uncertainty about the directness or extent to which the people, interventions and outcomes are similar to those of interest? Some (−1); major (−2); none (0) | −1
5 | Were the studies sparse or imprecise? y (−1); n (0) | 0
6 | Did the studies show strong evidence of association between intervention and outcome? “strong^*^” (+1); “very strong^†^” (+2); No (0) | 0
| Overall grade of evidence ‡ | Moderate

* if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders

† if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity

‡ (high, moderate, low):if above score is (+), increase grade; if above score is (−), decrease grade from high to moderate (−1) or low (−2).

### General Study Characteristics

The asthma studies involved children as young as 17 years of age8,10–12 while the contraception study participants were young women ( 20 yrs or younger). 9 One of the asthma studies involved a majority of female participants,10 the others had a majority of male participants.8,11,12 All of the asthma studies reported on race, one on caregiver education. The contraception study was conducted at two separate family planning clinic sites resulting in a highly diverse participant background in terms of race and socioeconomic status (Appendix G, Evidence Tables 2 and 3).

### Outcomes

#### Asthma

When evaluating therapeutic and monitoring adherence among children with asthma, Jan et al10 found that the children using the Blue Angel for Asthma Kids application, an Internet based interactive asthma program , monitored their peak expiratory flows and adhered to an asthma diary significantly more than those receiving standard asthma education including written diary and instructions for self management at 12 weeks ( p < 0.05) . Similarly their therapeutic adherence to inhaled corticosteroid treatment was significantly higher (63 percent among intervention vs. 42 percent among control group). In this intervention, participants received a self management plan from the Blue Angel program after entering their symptoms and peak flow measurement on a daily basis into the computer (Appendix G, Evidence Table 4).

Krishna et al8 showed a positive impact2 of an interactive computer program that delivers tailored educational messages in the form of brief vignettes for asthma education on health care utilization rates. This intervention was delivered in the clinic’s waiting area and required no change in clinic flow or staffing levels. In this study, all participants in the intervention and control group also received standard education based on the National Asthma Education and prevention program. Participants in the intervention arm had significantly fewer emergency room visits (1.93 vs. 0.62 per year, p<0.01,) and a significantly lower daily dose of inhaled corticosteroids (434 vs. 754 μg, p < 0.01) possibly due to improved avoidance of asthma triggers. No statistically significant difference was found for the number of hospitalizations. Increased knowledge levels about asthma in both the control and intervention arms positively correlated with fewer urgent visits to physicians and reduced use of quick relief medications (correlation coefficient r = 0.37 and 0.30, respectively)

Guendelman et al11 studied the impact of the Health Buddy (an interactive communication device) compared to an asthma diary on health related quality of life and health processes. This study demonstrated that the intervention group was significantly more likely to have no limitation of activity (p=0.03), significantly less likely to report peak flow readings in the yellow or red zone (p=.01) or to make urgent calls to the hospital (p=.05).

Finally Bartholomew et al12 evaluated an interactive multimedia computer game designed to enhance self-management skills and thereby improve asthma outcomes. The study demonstrated that the intervention group had fewer hospitalizations, better symptom scores, increased functional status, greater knowledge of asthma management, and better child self-management behavior as compared to controls at baseline. (Appendix G, Evidence Table 4).

#### Oral contraceptive use

In this study involving two family planning clinics, increased knowledge about oral contraceptive methods as a result of using a decision support aid did not reduce discontinuation rates for oral contraceptives among female adolescents (Appendix G, Evidence Table 4). Although not a primary outcome in this study, it is interesting to note that the reasons for discontinuation of oral contraceptives, however, were mainly medication side effects and changes in sexual relationships altering perceived need for using contraceptives.9

## Key Question 1b: What evidence exists that consumer health informatics applications impact intermediate outcomes?

### Breast Cancer

#### Summary of the Findings

Three studies examined the impact of CHI in the context of breast cancer (Table 3), 13–15 and one of these was a study of multiple cancers that included breast cancer.15 Outcomes examined were similar in two of the studies, which were from the same research group and involved the same CHI intervention (Comprehensive Health Enhancement Support System [CHESS]). These studies examined quality of life, as well as the woman’s perception of social support, unmet information needs, information competence, and involvement in her own health care.13,14 One additional study addressed satisfaction with the information, computer versus provider consultation preference, and anxiety and depression.15

Table 3

Results of studies of CHI applications impacting intermediate outcomes in breast cancer (N=3).

Target condition | N | Author, year | Interventions | Primary outcomes measured | Effect of CHI application^*^
Breast cancer | 3 | Jones, 1999^15^ | Computer-Personal Information via computer Computer - General information about cancer | Satisfaction Score >2, n(%) a few days after information given | +
Breast cancer | 3 | Jones, 1999^15^ | Computer-Personal Information via computer Computer - General information about cancer | Prefer computer to 10 minute consultation with professional (at 3 months of follow up)^†^ | −
Breast cancer | 3 | Gustafson, 2001^13^ | CHESS | Social Support | +
Breast cancer | 3 | Gustafson, 2001^13^ | CHESS | Information competence | 0
Breast cancer | 3 | Gustafson, 2001^13^ | CHESS | Unmet information needs | 0
Breast cancer | 3 | Gustafson, 2001^13^ | CHESS | Participation, behavioral involvement | +
Breast cancer | 3 | Gustafson, 2001^13^ | CHESS | Participation, level of comfort | +
Breast cancer | 3 | Gustafson, 2001^13^ | CHESS | Confidence in doctors | 0
Breast cancer | 3 | Gustafson, 2008^14^ | CHESS | Social support | +

* (+) positive impact of the CHI application on outcome; (−) negative impact of the CHI application on outcome; (0) no impact or not a significant of the CHI application on outcome

† A 10 minute professional consultation was preferred to the intervention, however, the group randomized to the internet group was more likely to prefer using it.

CHESS = Comprehensive Health Enhancement Support System

Over the longer term, CHESS participants reported better social support and information competence than the comparison groups.13,14 In the study comparing personalized computer information with two comparison groups -- general computer information and information booklets – patients given access to personalized information on the computer a few days after they were given information about their cancer were more satisfied than patients in the other two groups.

#### Strengths and Limitations of the Evidence

Only three studies examined intermediate outcomes in patients with breast cancer, and one included a spectrum of different types of cancer, with breast cancer patients representing about half of all patients. The test interventions and outcomes examined were identical or nearly so in two of the trials, with outcome measures designed to be short term. Sample sizes in each of these studies were modest. All three studies were randomized, with only one 15 providing the details of how the randomization sequence was generated (a random numbers table), and only one 14 providing details on how allocation was concealed (sealed envelopes). Intermediate outcomes were all self-reported, and masking of the patients was not possible. Dropouts and withdrawals over the study period were over 10 percent in the 2001 CHESS study, 13 and slightly less in the 1999 CHESS study, 14 and nearly 20 percent in the study by Jones and colleagues. 15 An intention-to-treat analysis was only performed in the 2008 CHESS study.14 Overall, these studies were given a low study quality score according to the Jadad criteria4 (See Appendix G, Evidence Table 1). The overall strength of this body of evidence was graded as low (Table 4) based on a modified version of the GRADE criteria”5 and Chapter 11 of the EPC Manual6

Table 4

Grade of the body of evidence addressing CHI impact on intermediate outcomes in breast cancer.

1 | Protection against risk of bias (relates to study design, study quality, reporting bias) | Moderate
2 | Number of studies | 3
3 | Did the studies have important inconsistency? y (−1); n (0) | 0
4 | Was there some (−1) or major (−2) uncertainty about the directness or extent to which the people, interventions and outcomes are similar to those of interest? Some (−1); major (−2); none (0) | 0
5 | Were the studies sparse or imprecise? y (−1); n (0) | −1
6 | Did the studies show strong evidence of association between intervention and outcome? “strong^*^” (+1); “very strong^†^” (+2); No (0) | 0
| Overall grade of evidence ‡ | Low

* if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders

† if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity

‡ (high, moderate, low):if above score is (+), increase grade; if above score is (−), decrease grade from high to moderate (−1) or low (−2).

#### General Study Characteristics

The studies identified were evaluations of the impact of CHI applications on intermediate outcomes tested among adult populations with cancer. One study included patients younger than 61^13^ (mean age about 44 years old), and the other two studies did not report patient ages. One study16 reported on the percent of “Caucasian” study participants – about 75 percent

#### Outcomes

In the 2001 CHESS study,13 patients allocated to CHESS reported statistically significantly greater social and information support, participation in health care, and confidence in the doctor, but not greater quality of life than patients with Internet access alone, at 2 months of followup. The positive effect of CHESS remained for social support at 5 months while no evidence of a beneficial effect of CHESS was observed at 5 months for information support, participation in health care, confidence in the doctor, or quality of life (Appendix G, evidence Table 7).

In the 2008 CHESS study,14 patients allocated to CHESS reported greater social support during the 5-month intervention period than did those offered books and audiotapes or those in the Internet access group. At 9 months, about 4 months after the intervention period ended, the CHESS group reported greater quality of life, social support, and health and information competence compared with the control group offered books and audiotapes, but not compared with the group given Internet access (Appendix G, evidence Table 7).

Jones et al15found that at the time the intervention was offered, more patients in the Internet groups (both personal and general information), found information more easily than those offered booklets, and those given booklets felt more overwhelmed by the information. However, respondents allocated to the computer groups more often found the information available too limited, compared to those assigned to the booklets. At 3 months of followup, all three groups overwhelmingly preferred a 10 minute professional consultation to use of the computer, although those assigned to the computer were more likely to prefer the computer (29 percent of those receiving personal information on the computer vs. 20 percent general information vs. 10 percent booklet information). At 3 months of followup, significantly more patients assigned to the general computer information group reported anxiety and depression (Appendix G, Evidence Table 7).

### Diet, Exercise, Physical Activity, not Obesity

#### Summary of the Findings

Thirty-two studies evaluated the impact of CHI applications on a variety of intermediate health outcomes related to diet, exercise, or physical activity, not obesity, including self-management, knowledge attainment (program adherence), and change in health behaviors (Table 5). The quality of these trials was highly variable with Jadad4 study quality scores ranging from very low to moderately high (although only one of the 32 articles was scored as moderately high) (Appendix G, Evidence Table 1). Included in the 32 studies were two studies that evaluated the impact of CHI applications on outcomes related to eating disorders, one of which focused specifically on overweight and binge eating,

Table 5

Results of studies on CHI applications impacting intermediate outcomes in diet, exercise, or physical activity, not obesity (N=32).

Target condition | N | Author, year | Interventions | Primary outcomes measured | Effect of CHI Application^*^
Diet, exercise, physical activity, not obesity | 32 | Adachi, 2007^*,17^ | Computer tailored program with 6-month weight and targeted behavior’s self-monitoring, Computer tailored program only | Body Weight | +
Diet, exercise, physical activity, not obesity | 32 | Adachi, 2007^*,17^ | Computer tailored program with 6-month weight and targeted behavior’s self-monitoring, Computer tailored program only | BMI | +
Diet, exercise, physical activity, not obesity | 32 | Adachi, 2007^*,17^ | Computer tailored program with 6-month weight and targeted behavior’s self-monitoring, Computer tailored program only | Percent weight loss | +
Diet, exercise, physical activity, not obesity | 32 | Anderson, 2001^18^ | Computer kiosk nutrition intervention | Fat (% calories) Composites Scores | 0
Diet, exercise, physical activity, not obesity | 32 | Anderson, 2001^18^ | Computer kiosk nutrition intervention | Fiber (g/1,000kcals) | 0
Diet, exercise, physical activity, not obesity | 32 | Anderson, 2001^18^ | Computer kiosk nutrition intervention | Fruit and vegetables (servings/1000kcals) | 0
Diet, exercise, physical activity, not obesity | 32 | Anderson, 2001^18^ | Computer kiosk nutrition intervention | Self Efficacy/Low-Fat Meals | 0
Diet, exercise, physical activity, not obesity | 32 | Anderson, 2001^18^ | Computer kiosk nutrition intervention | Self-Efficacy/Low-Fat Snacks | 0
Diet, exercise, physical activity, not obesity | 32 | Anderson, 2001^18^ | Computer kiosk nutrition intervention | Self-Efficacy/Fruit, Vegetables, Fiber | 0
Diet, exercise, physical activity, not obesity | 32 | Anderson, 2001^18^ | Computer kiosk nutrition intervention | Outcome Expectations/Appetite Satisfaction | 0
Diet, exercise, physical activity, not obesity | 32 | Anderson, 2001^18^ | Computer kiosk nutrition intervention | Outcome Expectations/Budgetary Outcomes | 0
Diet, exercise, physical activity, not obesity | 32 | Anderson, 2001^18^ | Computer kiosk nutrition intervention | Outcome Expectations/Health Outcomes | 0
Diet, exercise, physical activity, not obesity | 32 | Brug, 1996^19^ | Tailored feedback | Fat (points per day) | +
Diet, exercise, physical activity, not obesity | 32 | Brug, 1996^19^ | Tailored feedback | Vegetables (servings per day) | 0
Diet, exercise, physical activity, not obesity | 32 | Brug, 1996^19^ | Tailored feedback | Fruit (servings per day) | 0
Diet, exercise, physical activity, not obesity | 32 | Brug, 1996^19^ | Tailored feedback | Positive attitude to increasing vegetables and fruits | +
Diet, exercise, physical activity, not obesity | 32 | Brug, 1998^20^ | Computer-tailored fat, fruit, and vegetable intake intervention | Fat (fat points per day) | +
Diet, exercise, physical activity, not obesity | 32 | Brug, 1998^20^ | Computer-tailored fat, fruit, and vegetable intake intervention | Fruit (servings per day) | +
Diet, exercise, physical activity, not obesity | 32 | Brug, 1998^20^ | Computer-tailored fat, fruit, and vegetable intake intervention | Vegetables (servings per day) | 0
Diet, exercise, physical activity, not obesity | 32 | Brug, 1999^21^ | Computerized feedback on fat, fruit, and vegetable intake | Fat score | 0
Diet, exercise, physical activity, not obesity | 32 | Brug, 1999^21^ | Computerized feedback on fat, fruit, and vegetable intake | Servings of vegetables | +
Diet, exercise, physical activity, not obesity | 32 | Brug, 1999^21^ | Computerized feedback on fat, fruit, and vegetable intake | Servings of fruit | 0
Diet, exercise, physical activity, not obesity | 32 | Brug, 1999^21^ | Computerized feedback on fat, fruit, and vegetable intake | Intention to reduce fat intake | 0
Diet, exercise, physical activity, not obesity | 32 | Brug, 1999^21^ | Computerized feedback on fat, fruit, and vegetable intake | Intention to increase vegetable intake | 0
Diet, exercise, physical activity, not obesity | 32 | Campbell, 1994^22^ | Tailored nutrition intervention | Fat (g/day) | +
Diet, exercise, physical activity, not obesity | 32 | Campbell, 1999^23^ | Tailored multimedia intervention | Knowledge score of low fat foods | 0
Diet, exercise, physical activity, not obesity | 32 | Campbell, 1999^23^ | Tailored multimedia intervention | Self-efficacy | 0
Diet, exercise, physical activity, not obesity | 32 | Campbell, 1999^23^ | Tailored multimedia intervention | Fat score | 0
Diet, exercise, physical activity, not obesity | 32 | Campbell, 1999^23^ | Tailored multimedia intervention | Stage of change- Precontemplation | +
Diet, exercise, physical activity, not obesity | 32 | Campbell, 1999^23^ | Tailored multimedia intervention | Stage of change- Contemplation | 0
Diet, exercise, physical activity, not obesity | 32 | Campbell, 1999^23^ | Tailored multimedia intervention | Stage of change- Preparation | 0
Diet, exercise, physical activity, not obesity | 32 | Campbell, 1999^23^ | Tailored multimedia intervention | Stage of change- Action/maintenance | 0
Diet, exercise, physical activity, not obesity | 32 | Campbell, 2004^24^ | Computer based interactive nutrition education | Total Low-fat knowledge score | +
Diet, exercise, physical activity, not obesity | 32 | Campbell, 2004^24^ | Computer based interactive nutrition education | Total Infant feeding knowledge score | +
Diet, exercise, physical activity, not obesity | 32 | Campbell, 2004^24^ | Computer based interactive nutrition education | Total self-efficacy score | 0
Diet, exercise, physical activity, not obesity | 32 | Haerens, 2005^25^ | CD-ROM based nutrition support | Fat intake (g/day, day 21) | 0
Diet, exercise, physical activity, not obesity | 32 | Haerens, 2005^25^ | CD-ROM based nutrition support | Fruit intake (pieces week) | 0
Diet, exercise, physical activity, not obesity | 32 | Haerens, 2005^25^ | CD-ROM based nutrition support | Soft drinks (glasses day) | 0
Diet, exercise, physical activity, not obesity | 32 | Haerens, 2005^25^ | CD-ROM based nutrition support | Water (glasses/day, day 21) | 0
Diet, exercise, physical activity, not obesity | 32 | Haerens, 2005^25^ | CD-ROM based nutrition support | Pre- and post-test intake levels for fat intake in girls | +
Diet, exercise, physical activity, not obesity | 32 | Haerens, 2005^25^ | CD-ROM based nutrition support | Pre- and post-test intake levels (mean ^ SD) for % energy from fat in girls | +
Diet, exercise, physical activity, not obesity | 32 | Haerens, 2007^26^ | Computer tailored intervention | Dietary fat intake | 0
Diet, exercise, physical activity, not obesity | 32 | Haerens, 2009^27^ | Computer-tailored exercise intervention | Cycling for transportation | 0
Diet, exercise, physical activity, not obesity | 32 | Haerens, 2009^27^ | Computer-tailored exercise intervention | Walking for transportation | 0
Diet, exercise, physical activity, not obesity | 32 | Haerens, 2009^27^ | Computer-tailored exercise intervention | Walking in leisure time | 0
Diet, exercise, physical activity, not obesity | 32 | Haerens, 2009^27^ | Computer-tailored exercise intervention | Total moderate to vigorous activity | 0
Diet, exercise, physical activity, not obesity | 32 | Hurling, 2006^28^ | Internet-based exercise motivation | Change in perception of exercise | +
Diet, exercise, physical activity, not obesity | 32 | Hurling, 2006^28^ | Internet-based exercise motivation | Change in ratings of expectation; satisfaction with motivation to exercise | +
Diet, exercise, physical activity, not obesity | 32 | Hurling, 2006^28^ | Internet-based exercise motivation | The mean change in ratings of the statement “I am very satisfied with my current level of motivation to do exercise’ | 0
Diet, exercise, physical activity, not obesity | 32 | Hurling, 2007^29^ | Had access to Internet and mobile phone | MET min/week | 0
Diet, exercise, physical activity, not obesity | 32 | Hurling, 2007^29^ | Had access to Internet and mobile phone | Change in weekly hours spent sitting (MET min/week leisure time) | +
Diet, exercise, physical activity, not obesity | 32 | Jones, 2008^30,§^ | Student Bodies 2 -BED | BMI | +
Diet, exercise, physical activity, not obesity | 32 | Jones, 2008^30,§^ | Student Bodies 2 -BED | BMIzScore | +
Diet, exercise, physical activity, not obesity | 32 | Jones, 2008^30,§^ | Student Bodies 2 -BED | Binge eating (OBEs and SBEs) | +
Diet, exercise, physical activity, not obesity | 32 | Jones, 2008^30,§^ | Student Bodies 2 -BED | Binge eating (OOEs) | 0
Diet, exercise, physical activity, not obesity | 32 | Jones, 2008^30,§^ | Student Bodies 2 -BED | Weight and shape concerns | +
Diet, exercise, physical activity, not obesity | 32 | Jones, 2008^30,§^ | Student Bodies 2 -BED | Dietary fat intake | 0
Diet, exercise, physical activity, not obesity | 32 | Jones, 2008^30,§^ | Student Bodies 2 -BED | Depressed mood | 0
Diet, exercise, physical activity, not obesity | 32 | King, 2006^31^ | Interactive CD-ROM for health risk appraisal | Total physical activity | +
Diet, exercise, physical activity, not obesity | 32 | King, 2006^31^ | Interactive CD-ROM for health risk appraisal | Moderate physical activity | +
Diet, exercise, physical activity, not obesity | 32 | Kristal 2000^32^ | Computer-generated personalized letter for fruit and vegetable intake | Fat-related diet habit | +
Diet, exercise, physical activity, not obesity | 32 | Kristal 2000^32^ | Computer-generated personalized letter for fruit and vegetable intake | Fruit and vegetables (servings/day) | +
Diet, exercise, physical activity, not obesity | 32 | Lewis, 2008^33^ | Internet-based physical activity program | median number of logins | +
Diet, exercise, physical activity, not obesity | 32 | Lewis, 2008^33^ | Internet-based physical activity program | 5-itemWebsite Quality Questionnaire | +
Diet, exercise, physical activity, not obesity | 32 | Low, 2006^34^ | Student bodies with a moderated discussion group Un-moderated discussion group Program alone | EDI- Bulimia | +
Diet, exercise, physical activity, not obesity | 32 | Low, 2006^34^ | Student bodies with a moderated discussion group Un-moderated discussion group Program alone | EDI-Body Dissatisfaction | +
Diet, exercise, physical activity, not obesity | 32 | Low, 2006^34^ | Student bodies with a moderated discussion group Un-moderated discussion group Program alone | Weight and Shape Concerns | +
Diet, exercise, physical activity, not obesity | 32 | Marcus, 2007^35^ | Tailored Internet Standard Internet | Physical activity per week | 0
Diet, exercise, physical activity, not obesity | 32 | Marcus, 2007^35^ | Tailored Internet Standard Internet | Improvement in functional capacity (estimated volume 0_2_ at 85% of predicted maximum heart rate)(ml/kg per minute) | 0
Diet, exercise, physical activity, not obesity | 32 | Marcus, 2007^35^ | Tailored Internet Standard Internet | 150 minutes of physical activity per week | 0
Diet, exercise, physical activity, not obesity | 32 | Mangunkusumo, 2007^36^ | Internet Group | Evaluation of Health | 0
Diet, exercise, physical activity, not obesity | 32 | Mangunkusumo, 2007^36^ | Internet Group | Evaluation of Fruit Advice (pleasant) (Likert Scale) | +
Diet, exercise, physical activity, not obesity | 32 | Mangunkusumo, 2007^36^ | Internet Group | Acceptability (Was fruit advice targeted to you?) | +
Diet, exercise, physical activity, not obesity | 32 | Mangunkusumo, 2007^36^ | Internet Group | Acceptability (Did you enjoy it?) | +
Diet, exercise, physical activity, not obesity | 32 | Mangunkusumo, 2007^36^ | Internet Group | Quality of Intervention (relevant) | 0
Diet, exercise, physical activity, not obesity | 32 | Mangunkusumo, 2007^36^ | Internet Group | Quality of Intervention (credible) | +
Diet, exercise, physical activity, not obesity | 32 | Mangunkusumo, 2007^36^ | Internet Group | Quality of Intervention (useful) | +
Diet, exercise, physical activity, not obesity | 32 | Napolitano, 2003^37^ | Internet intervention | Minutes moderate physical activity | +
Diet, exercise, physical activity, not obesity | 32 | Napolitano, 2003^37^ | Internet intervention | Minutes, walking | +
Diet, exercise, physical activity, not obesity | 32 | Napolitano, 2003^37^ | Internet intervention | Stage of change, progression | +
Diet, exercise, physical activity, not obesity | 32 | Oenema, 2001^38^ | Web based tailored nutrition education | Intention to eat less fat | +
Diet, exercise, physical activity, not obesity | 32 | Oenema, 2001^38^ | Web based tailored nutrition education | Self-rated fat intake compared to others | +
Diet, exercise, physical activity, not obesity | 32 | Oenema, 2001^38^ | Web based tailored nutrition education | Self-rated fruit intake | +
Diet, exercise, physical activity, not obesity | 32 | Oenema, 2001^38^ | Web based tailored nutrition education | Self rated fat intake | +
Diet, exercise, physical activity, not obesity | 32 | Oenema, 2001^38^ | Web based tailored nutrition education | Self rated fruit intake compared to others | +
Diet, exercise, physical activity, not obesity | 32 | Oenema, 2001^38^ | Web based tailored nutrition education | Self-rated vegetable intake | 0
Diet, exercise, physical activity, not obesity | 32 | Oenema, 2001^38^ | Web based tailored nutrition education | Self-rated vegetable intake compared to others | 0
Diet, exercise, physical activity, not obesity | 32 | Richardson, 2007^39^ | Group receiving tailored feedback on lifestyle goals | Total Steps | 0
Diet, exercise, physical activity, not obesity | 32 | Richardson, 2007^39^ | Group receiving tailored feedback on lifestyle goals | Bout Steps | 0
Diet, exercise, physical activity, not obesity | 32 | Silk, 2008^40^ | Web site Video game | Likeability of learning materials (hypothesis 1) [authors identify 3 subscales -- attention, understanding, intention] | +
Diet, exercise, physical activity, not obesity | 32 | Silk, 2008^40^ | Web site Video game | Nutrition literacy scores (hypothesis 2) [authors identify 6 subscales: MyPyramid, Food groups, Food servings, Serving size, Food safety, Food cost] | +
Diet, exercise, physical activity, not obesity | 32 | Smeets, 2007^41^ | Intervention group, receiving one tailored letter | Fat consumption (gm) | +
Diet, exercise, physical activity, not obesity | 32 | Smeets, 2007^41^ | Intervention group, receiving one tailored letter | Fruit consumption (pieces/day) | +
Diet, exercise, physical activity, not obesity | 32 | Spittaels, 2007^42^ | On-line tailored Physical activity advice+ stage based reinforcement emails On-line tailored physical activity advice | Increase in total physical activity | +
Diet, exercise, physical activity, not obesity | 32 | Spittaels, 2007^42^ | On-line tailored Physical activity advice+ stage based reinforcement emails On-line tailored physical activity advice | Increase in moderate to vigorous physical activity | +
Diet, exercise, physical activity, not obesity | 32 | Spittaels, 2007^42^ | On-line tailored Physical activity advice+ stage based reinforcement emails On-line tailored physical activity advice | Increase in physical activity in leisure time | +
Diet, exercise, physical activity, not obesity | 32 | Spittaels, 2007^43^ | Website with computer tailored feedback on physical activity | Total moderate to vigorous physical activity scores | 0
Diet, exercise, physical activity, not obesity | 32 | Tate, 2006^44,†^ | Tailored Computer-Automated Feedback Human Email Counseling | Dietary intake (kcal/day) | +
Diet, exercise, physical activity, not obesity | 32 | Tate, 2006^44,†^ | Tailored Computer-Automated Feedback Human Email Counseling | Fat intake (% day) | +
Diet, exercise, physical activity, not obesity | 32 | Tate, 2006^44,†^ | Tailored Computer-Automated Feedback Human Email Counseling | Physical activity (kcal/week) | +
Diet, exercise, physical activity, not obesity | 32 | Vandelanotte, 2005^45^ | Sequential interactive computer tailored intervention Simultaneous interactive computer tailored intervention | Increase physical activity | +
Diet, exercise, physical activity, not obesity | 32 | Vandelanotte, 2005^45^ | Sequential interactive computer tailored intervention Simultaneous interactive computer tailored intervention | Decrease fat intake | +
Diet, exercise, physical activity, not obesity | 32 | Verheijden, 2004^46^ | Web-Based Targeted nutrition counseling and social support | Perceived support | 0
Diet, exercise, physical activity, not obesity | 32 | Verheijden, 2004^46^ | Web-Based Targeted nutrition counseling and social support | Social network | 0
Diet, exercise, physical activity, not obesity | 32 | Verheijden, 2004^46^ | Web-Based Targeted nutrition counseling and social support | BMI ( kg/m^2^) | 0
Diet, exercise, physical activity, not obesity | 32 | Verheijden, 2004^46^ | Web-Based Targeted nutrition counseling and social support | Systolic blood pressure | 0
Diet, exercise, physical activity, not obesity | 32 | Verheijden, 2004^46^ | Web-Based Targeted nutrition counseling and social support | Diastolic blood pressure | 0
Diet, exercise, physical activity, not obesity | 32 | Verheijden, 2004^46^ | Web-Based Targeted nutrition counseling and social support | Total cholesterol | 0
Diet, exercise, physical activity, not obesity | 32 | Winzelberg, 2000^47,**^ | Internet-delivered computer-assisted health education program | Body Shape Measure | +
Diet, exercise, physical activity, not obesity | 32 | Winzelberg, 2000^47,**^ | Internet-delivered computer-assisted health education program | EDI-drive for thinness | +
Diet, exercise, physical activity, not obesity | 32 | Winzelberg, 2000^47,**^ | Internet-delivered computer-assisted health education program | EDI-Bulimia | 0
Diet, exercise, physical activity, not obesity | 32 | Winzelberg, 2000^47,**^ | Internet-delivered computer-assisted health education program | EDE-Q Weight Concerns | 0
Diet, exercise, physical activity, not obesity | 32 | Winzelberg, 2000^47,**^ | Internet-delivered computer-assisted health education program | EDE-Q Shape Concern | 0
Diet, exercise, physical activity, not obesity | 32 | Winzelberg, 2000^47,**^ | Internet-delivered computer-assisted health education program | Saturated Fat (g/day) | +
Diet, exercise, physical activity, not obesity | 32 | Winzelberg, 2000^47,**^ | Internet-delivered computer-assisted health education program | Vegetable/Fruit (servings/day) | +
Diet, exercise, physical activity, not obesity | 32 | Wylie-Rosett, 2001^48^ | Computer tailored lifestyle modification | Dietary Intake | 0
Diet, exercise, physical activity, not obesity | 32 | Wylie-Rosett, 2001^48^ | Computer tailored lifestyle modification | Exercise (Blocks walked daily) | 0
Diet, exercise, physical activity, not obesity | 32 | Wylie-Rosett, 2001^48^ | Computer tailored lifestyle modification | Exercise (min walked continuously) | 0
Diet, exercise, physical activity, not obesity | 32 | Wylie-Rosett, 2001^48^ | Computer tailored lifestyle modification | Weight (lb) | +
Diet, exercise, physical activity, not obesity | 32 | Wylie-Rosett, 2001^48^ | Computer tailored lifestyle modification | BMI | +

* (+) positive impact of the CHI application on outcome; (−) negative impact of the CHI application on outcome; (0) no impact or not a significant of the CHI application on outcome

† There were significant effects of human email counseling and computer-automated counseling on decrease in fat intake when compared to control; however, no treatment difference between the human email counseling and computer-automated counseling were demonstrated.

‡ Long-term effects of a 1-month behavioral weight control program assisted by computer tailored advice with weight and targeted behavior self-monitoring were more effective when compared to the behavioral weight control program assisted by computer tailored advice alone, an untailored self-help booklet with self-monitoring of weight and walking, and a self-help booklet alone.

§ study focuses on binge eating and overweight

|| z score: “A z-score is the deviation of the value for an individual from the mean value of the reference population divided by the standard deviation for the reference population. Because z-scores have a direct relationship with percentiles, a conversion can occur in either direction using a standard normal distribution table. Therefore, for every z-score there is a corresponding percentile and vice versa.”49

** Study focused on eating disorders.

BMI=body mass index; EDE-Q = Eating Disorder Examination—Questionnaire; EDI = Eating Disorder Inventory; g/day = grams per day; gm = gram; g/1,000 = grams per 1,000; kcal = kilocalorie; kg/m2 = kilogram per meter squared; lb = pound; ml/kg = milliliters per kilogram ; min/wk = minutes per week; OBE= objective binge episode; OOE= objective overeating episode; SBE= subjective binge episode; SD = standard deviation

#### Strengths and Limitations of the Evidence

Twenty-nine studies are available to evaluate CHI impact on intermediate health outcomes within the context of diet, exercise, or physical activity, not obesity. Additionally two studies were available to evaluate impact within the contexts of eating disorders and one study was available to evaluate the impact in the context of overweight and binge eating. Limitations included the occasional imprecision of study results due to wide-ranging confidence intervals. Many, though not all of these studies relied on very small sample sizes. (Appendix G, Evidence Tables 8–10). The overall strength of the body of this evidence (Table 6) on the impact of CHI applications on diet, exercise, or physical activity, not obesity was graded as moderate based on a modified version of the GRADE criteria5 and Chapter 11 of the EPC Manual6 All of the studies were included in this grading of the evidence because they all had at least one outcome relevant to the effects on diet, exercise, or physical activity, not obesity.

Table 6

Grade of the body of evidence addressing CHI impacts on intermediate outcomes in diet, exercise, nutrition intervention (not obesity).

1 | Protection against risk of bias (relates to study design, study quality, reporting bias) | High
2 | Number of studies | 32
3 | Did the studies have important inconsistency? y (−1); n (0) | 0
4 | Was there some (−1) or major (−2) uncertainty about the directness or extent to which the people, interventions and outcomes are similar to those of interest? Some (−1); major (−2); none (0) | 0
5 | Were the studies sparse or imprecise? y (−1); n (0) | −1
6 | Did the studies show strong evidence of association between intervention and outcome? “strong^*^” (+1); “very strong^†^” (+2); No (0) | 0
| Overall grade of evidence ‡ | Moderate

* if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders

† if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity

‡ (high, moderate, low):if above score is (+), increase grade; if above score is (−), decrease grade from high to moderate (−1) or low (−2).

#### General Study Characteristics

The studies on the impact of CHI applications on intermediate health outcomes were generally conducted among adult, non-elderly populations. Five studies however were conducted specifically among adolescent populations 25,26,27, 25,27,30,36 (Appendix G, Evidence Tables 8 and 9).

Many studies were conducted among female participants. When reported, the race/ethnicity of respondents was generally such that the majority of subjects identified as Caucasian, with smaller percentages of Asian, Native American, African American or Black, or other groups reported. Educational level varied, with higher rates of higher education within studies conducted among young adults in the workplace or on college campuses. Patient post-intervention evaluation ranged from as little as immediately post-test to as long as twelve months. Upon review, the body of scientific evidence from these studies indicated that most CHI applications evaluated to date had effects on intermediate health outcomes (Appendix G, Evidence Tables 8 and 9).

#### Outcomes

##### Diet, exercise, or physical activity, not obesity

Haerens et al25 evaluated the effects of a middle-school healthy eating promotion intervention combining environmental changes and computer-tailored feedback, with and without an explicit parent involvement component. This study demonstrated that in girls, fat intake and percentage of energy from fat decreased significantly more in the intervention group with parental support, compared with the intervention alone group (p = 0.05) and the control group (p=0.001). No impacts were found in boys or in girls for fruit, soft drinks, and water consumption.

In another study by Haerens et al27 evaluated the differences in effects of a computer tailored physical activity advice as compared to providing generic information among adolescents. After 4 weeks, most physical activity scores increased in both groups. No differences between groups were found. After 3 months, the generic intervention was more effective at increasing “walking in leisure time” among students not complying with recommendations. For all other physical activity scores, no differences between groups were found.

In a third study Haerens et al 26 investigated a computer-tailored dietary fat intake intervention for adolescents as compared to control and found no intervention effects for the total sample.

Marcus et al 35 investigated the effects of an internet-based tailored physical activity intervention, a standard internet physical activity intervention, and a tailored print physical activity intervention and found that all groups increased physical activity behavior similarly and no significant treatment effects were detected between groups.

When evaluating behavior change regarding changes in weekly hours spent sitting, Hurling et al29 found that an Internet and mobile phone technology delivering an automated physical activity program was associated with greater perceived control and intention/expectation to exercise when compared to a control group than those who received no support (p<0.001) (Appendix G, Evidence Table 10).

Regarding a decrease in fat consumption and increase in fruit consumption, Smeets et al41 found that a computer tailored intervention was associated with these behaviors at 3 months (p<0.05 and p<0.01, respectively). While this intervention did not enhance the health behaviors, it did reduce the decline in these behaviors over the followup period (Appendix G, Evidence Table 10).

Spittaels et al42 found that an increase in total physical activity, increase in moderate to vigorous physical activity, increase in physical activity during leisure time, and decrease in body fat were behaviors more strongly associated with use of an online-tailored physical activity advice program with stage-based reinforcement emails when compared to online-tailored physical activity advice without reinforcement emails or on-line non-tailored standard physical activity advice (p<0.001, p<0.05, p<0.001, and p<0.05, respectively) (Appendix G, Evidence Table 10).

Tate et al 44 investigated the effects of human e-mail counseling, computer-automated tailored counseling, and no counseling in an internet weight loss program. Significant effects of human email counseling and computer-automated counseling on decrease in fat intake when compared to control were demonstrated at 3 and 6 months (p<0.04 and p<0.004, respectively); however, no treatment difference between the human email counseling and computer-automated counseling were demonstrated. (Appendix G, Evidence Table 10)

Mangunkusumo et al36 found that Internet-administered adolescent health promotion in a preventive-care setting was more effective when compared to a control of usual practice with paper and pencil for some outcomes but not for others. Subjects found the Internet-tailored fruit advice more pleasant, easy to use, personally targeted, and enjoyable but less credible when compared to generic preprinted advice (p<0.01) (Appendix G, Evidence Table 10).

Adachi et al17 found that the long-term effects of a 1-month behavioral weight control program assisted by computer tailored advice with weight and targeted behavior self-monitoring was more effective when compared to the behavioral weight control program assisted by computer tailored advice alone, an untailored self-help booklet with self-monitoring of weight and walking, and a self-help booklet alone. While dietary habits and physical activity were improved in all subjects, the mean weight loss associated with these improvements was greatest in the behavioral weight control program assisted by computer tailored advice with weight and targeted behavior self-monitoring (p<0.05) (Appendix G, Evidence Table 10).

Vandelanotte et al45 found that sequential and simultaneous interactive computer-tailored interventions were more effective when compared to a control group for producing higher physical activity scores and lower fat intake scores (p<0.001) (Appendix G, Evidence Table 10).

Verheijden et al 46 investigated Web-based targeted nutrition counseling and social support for patients at increased cardiovascular risk in general practice as compared to control treatment of usual care and found no significant treatment differences in outcomes (Appendix G, Evidence Table 10).

In another study, Oenema et al38 found that a Web-based tailored nutrition education intervention had greater effect on self-rated fruit intake compared to others as well as intention to eat less fat when compared to a control group at post-test (p<0.01, p<0.05, and p<0.01, respectively) (Appendix G, Evidence Table 10).

Napolitano et al37 found that an Internet-based physical activity intervention was more strongly associated with progression in stage of motivational readiness for physical activity when compared with a control group at one month (p<0.05) and at three months (p<0.01). Additionally, the Internet-based physical activity intervention was also more strongly associated with increases in walking minutes when compared with a control group at one month (p<0.001) and at three months (p<0.05) (Appendix G, Evidence Table 10).

Caroline et al39 evaluated the effect of technology enhanced pedometers and interactive, tailored, Web based, feedback on physical activity among sedentary adults with Type II Diabetes. Individuals in all groups increased their physical activity from baseline, however no significant between group differences were achieved.

In a study conducted with patients attending family practice clinics in North Carolina Campbell et al22 tested the effect of individually computer-tailored messages designed to decrease fat intake and increase fruit and vegetable intake. At 4 month followup, the data indicated that the tailored intervention produced significant decreases in total fat and saturated fat scores compared with those of the control group p<0.05). Fruit and vegetable consumption did not increase in any study group.

Kristal et al32 evaluated a tailored, multiple-component self-help intervention designed to promote lower fat and higher fruit and vegetable consumption .The intervention consisted of a computer-generated personalized letter and behavioral feedback, a motivational phone call, a self-help manual and newsletters and was compared to a no material control. The intervention significantly reduced fat intake (p<0.001) and significantly increased fruit and vegetable intake (p<0.001) as compared to controls.

Hurling et al28 evaluated an Internet-based exercise motivation and action support system (Test system), relative to a group receiving no intervention (Reference) and another receiving a less interactive version of the same system (Control). Seven months after the intervention, participants who used the test system reported greater levels of increase in exercise motivation than the control or reference groups (p < 0.05).

Brug et al21 evaluated the impact of two computer-tailored nutrition education interventions and tailored psychosocial feedback compared to computer tailored nutrition education alone, regarding reducing their fat consumption and increasing consumption of fruit and vegetables. No significant differences in consumption of fat, fruit, and vegetables were found.

In another study by Brug et al20 the impact of individualized computer-generated nutrition information and additional effects of iterative feedback on changes in intake of fat, fruits, and vegetables was evaluated. The experimental group received computer-generated, tailored dietary feedback letters. Half of the experimental group received additional iterative tailored feedback. Controls received a single general nutrition information letter. The results indicated that Computer-tailored feedback had a significantly greater impact on fat reduction (p<0.01) and increased fruit (p<0.01) and vegetable intake (p<0.01) than did general information. Iterative computer-tailored feedback had an additional impact on fat intake (p=0.02).

Anderson et al18 studied the impact of a self administered computer tailored nutrition intervention. The application was located in kiosks and involved local grocery store shoppers. The results indicate that while an immediate post test suggested that individuals in the intervention group were more likely to attain dietary fat (p<0.001), fiber (p<0.001), fruits and vegetable consumption goals (p<0.05), they were only more likely to achieve dietary fat (p<0.05) and fiber (p<0.01) goals at follow up.

Campbell et al23 evaluated a tailored multimedia program designed to improve dietary behavior among low income women. The computer-based intervention consisted of a tailored soap opera and interactive ‘infomercials’ that provided individualized feedback about dietary fat intake, knowledge and strategies for lowering fat based on stage of change. Results from this study indicate that the intervention group participants had improved significantly in knowledge (P < 0.001), stage of change (P < 0.05) and certain eating behaviors (P < 0.05) compared to the control group.

In another study Campbell et al24 evaluated a tailored nutrition education CDROM program for participants in the Special Supplemental Nutrition Program for Women, Infants, and Children (WIC). Results from this study indicate that intervention group members increased self-efficacy (p<0.01) and scored significantly higher (p<0.05) on both low-fat and infant feeding knowledge compared with controls. No differential effect was observed for dietary intake variables.

Lewis et al33 evaluated the impact of instantaneous Web-based tailored feedback vs. general Websites currently available to the public among sedentary adults. The results indicated that individuals in the intervention group logged onto their Website significantly more times than the general Website controls (median 50 vs. 38; pb.05). Among participants in the intervention, the self-monitoring feature (i.e., logging) followed by goal setting were rated as the most useful Website components.

King et al31 evaluated the impact of a computer-assisted, tailored self-management physical activity intervention compared with health risk appraisal with feedback on sedentary adults with Type II Diabetes. At 2-month post intervention follow-up, the intervention significantly improved all physical activity (p<0.01) and moderate physical activity (metabolic equivalents > 3.0, p<0.01) relative to controls.

Spittaels et al43 evaluated a Website-delivered physical activity intervention, that provides participants with computer-tailored feedback, to ascertain the impact of the intervention on physical activity in the general population. Potential participants were allocated to one of three study groups. Participants in group 1 and 2 received the tailored physical activity advice on their computer screen immediately following their baseline assessment with the option to visit other Website sections. Participants in group 1 also received non-tailored e-mails inviting them to visit a specific Website section by following a hyperlink. Group 3 was a delayed treatment control group. Participants in both intervention groups reported a significant increase in transportation (movement, walking or running) (p<0.05), leisure time physical activity levels (p<0.05), and decrease in time spent sitting (p<0.05) at 6-month follow-up compared with the control group.

Wilie-Rosett et al48 evaluated the impact on weight loss of kiosk-based computer-tailored behavioral feedback versus the computer feedback plus in-person consultation versus a print workbook control. The results indicate that all groups had a significant decrease in energy and fat intake and increased physical activity (p<0.01). The greater the intensity of the intervention, the greater the increase or decrease.

When evaluating likeability of learning materials and nutrition literacy attainment, Silk et al40 found that an interactive Web site modality was associated with higher scores among participants when compared with a computer game and an information pamphlet at 2 weeks (p<0.05) (Appendix G, Evidence Table 10).

When evaluating reduction of fat intake and positive attitudes regarding this behavior, Brug et al19 found that a computer-tailored nutrition intervention with tailored feedback letters was more strongly associated with these outcomes when compared to a control group receiving general nutrition information at three weeks (p<0.01) (Appendix G, Evidence Table 10).

##### Eating Disorder

When evaluating drive for thinness and body shape concerns, Winzelberg et al47 found that the Internet-delivered computer–assisted health education program Student Bodies was associated with a decrease in these behaviors when compared to a control group at three months (p<0.05 and p<0.01, respectively) (Appendix G, Evidence Table 10).

Low et al34 found that decreases in self-reported bulimia, body dissatisfaction concerns, and weight and shape concerns were more strongly associated with the use of a computer-based interactive eating disorder prevention program (Student Bodies) with an unmoderated discussion group when compared to the Student Bodies program with a moderated discussion group, the Student Bodies program alone, or a control group (p<0.05) (Appendix G, Evidence Table 10).

##### Overweight and binge eating

When evaluating binge eating behaviors and concern with weight and shape, Jones et al30 found that the Internet-facilitated intervention Student Bodies2-Binge Eating Disorder (SB2-BED) was associated with a decrease in these behaviors when compared to a wait-list control at 16 weeks (p<0.05) (Appendix G, Evidence Table 10).

### Alcohol Abuse and Smoking Cessation

#### Summary of the Findings

Twenty-six studies evaluated the impact of CHI applications on a variety of intermediate health outcomes related to the use of alcohol and tobacco (Table 7). Outcomes of interest include self-management, knowledge attainment (program adherence), and change in health behaviors. The quality of these 26 trials was good. All were RCTs with sample sizes ranging from 83 to 288 respondents for the alcohol abuse studies and ranging from 139 to 3971 respondents for the tobacco use studies. Post-intervention evaluation ranged from as little as 30 days to as long as 24 months. Upon review, the body of scientific evidence from these studies indicates that most CHI applications evaluated to date had statistically significant effects on intermediate health outcomes.

Table 7

Results of studies on CHI applications impacting intermediate outcomes in alcohol abuse and smoking (N=26).

Target condition | N | Author, year | Interventions | Primary outcomes measured | Effect of CHI Application^*^
Alcohol abuse | 7 | Cunningham, 2005^‡,55^ | Internet plus self help book | Mean drinks per typical week | +
Alcohol abuse | 7 | Cunningham, 2005^‡,55^ | Internet plus self help book | Mean AUDIT test score | +
Alcohol abuse | 7 | Cunningham, 2005^‡,55^ | Internet plus self help book | Mean # of alcohol consequences | +
Alcohol abuse | 7 | Hester, 2005^56^ | DCU/Immediate treatment group | Average drinks per day | +
Alcohol abuse | 7 | Hester, 2005^56^ | DCU/Immediate treatment group | Drinks per drinking day | 0
Alcohol abuse | 7 | Hester, 2005^56^ | DCU/Immediate treatment group | Average peak BAC | +
Alcohol abuse | 7 | Kypri, 1999^51^ | Computerized Assessment and Behavioral Intervention | Drinking Frequency | +
Alcohol abuse | 7 | Lieberman, 2006^57^ | Multimedia | Number of modules complete | +
Alcohol abuse | 7 | Lieberman, 2006^57^ | Multimedia | Perceived helpfulness of the modules | 0
Alcohol abuse | 7 | Neighbors, 2004^52^ | Computerized normative feedback | Effect size in perceived norms | 0
Alcohol abuse | 7 | Neighbors, 2004^52^ | Computerized normative feedback | Effect size in reduction in alcohol consumption | +
Alcohol abuse | 7 | Neighbors, 2004^52^ | Computerized normative feedback | Effect size in reduction in alcohol consumption | +
Alcohol abuse | 7 | Riper, 2008^58^ | Intervention condition DL | Weekly alcohol consumption (second outcomes) | +
Alcohol abuse | 7 | Riper, 2008^59^ | Web-based self-help intervention without therapist guidance | Mean alcohol consumption at 6 months and 12 months follwup | +
Smoking | 19 | An, 2008^53^ | Real U^‡^ intervention | Percent abstinent for 30 days | +
Smoking | 19 | Brendryen, 2008 60 | Happy ending program—internet delivered smoking cessation | Repeated Points of Abstinence (1 + 3 + 6 + 12 months) | +
Smoking | 19 | Curry, 1995 61 | Computer-generated tailored feedback | 7-day abstinence at 21 months | 0
Smoking | 19 | Curry, 1995 61 | Computer-generated tailored feedback | Abstinent at 3, 12 and 21 months | 0
Smoking | 19 | Dijkstra, 2005^62^ | Computer tailored letters | Affective attitude | +
Smoking | 19 | Dijkstra, 2005^62^ | Computer tailored letters | Cognitive attitude | +
Smoking | 19 | Dijkstra, 2005^62^ | Computer tailored letters | Quitting attempts | +
Smoking | 19 | Hang, 2009 63 | Personalize smoking cessation via SMS | Number of cigarettes smoked per day
Smoking | 19 | Hang, 2009 63 | Personalize smoking cessation via SMS | 24 hour quit attempt | 0
Smoking | 19 | Hang, 2009 63 | Personalize smoking cessation via SMS | 24 hour quit attempt | 0
Smoking | 19 | Japuntich, 2006^64^ | CHESS SCRP | Abstinent | 0
Smoking | 19 | Pattens, 2006^54^ | Internet based intervention | Smoking abstinence | 0
Smoking | 19 | Prochaska, 1993 65 | Interactive computer support | Point Prevalence Abstinence, Precontemplation stage | 0
Smoking | 19 | Prochaska, 1993 65 | Interactive computer support | Point Prevalence Abstinence, Contemplation stage | 0
Smoking | 19 | Prochaska, 1993 65 | Interactive computer support | Point Prevalence Abstinence, Preparation stage | 0
Smoking | 19 | Prokhorov, 2008 66 | CD-ROM smoking cessation | Smoking initiation rates at 18 months (nonsmokers at baseline) | 0
Smoking | 19 | Prokhorov, 2008 66 | CD-ROM smoking cessation | Smoking cessation rates at 18 months (smokers at BL) | 0
Smoking | 19 | Severson, 2008^67^ | Interactive, tailored Web-based intervention | Tobacco abstinence (complete case) | +
Smoking | 19 | Severson, 2008^67^ | Interactive, tailored Web-based intervention | Tobacco abstinence (intent-to-treat) | +
Smoking | 19 | Severson, 2008^67^ | Interactive, tailored Web-based intervention | Smokeless tobacco use abstinence (complete case) | +
Smoking | 19 | Severson, 2008^67^ | Interactive, tailored Web-based intervention | Smokeless tobacco use abstinence (intent-to-treat) | +
Smoking | 19 | Schiffman, 2000^68^ | Computer tailored smoking cessation materials | Abstinence rates | +
Smoking | 19 | Schumann, 2006 69 | Computer generated tailored letters | Average probability of progression (precontemplation and contemplation) | 0
Smoking | 19 | Schumann, 2006 69 | Computer generated tailored letters | Average probability of regression (precontemplation and contemplation) | 0
Smoking | 19 | Schumann, 2008^70^ | Computer-tailored smoking cessation intervention | Point-prevalence abstinence | 0
Smoking | 19 | Schumann, 2008^70^ | Computer-tailored smoking cessation intervention | Prolonged abstinence | 0
Smoking | 19 | Strecher, 2008^71^ | High depth efficacy expectation Low depth efficacy expectation | Depth of efficacy expectation of smoking cessation intervention | 0
Smoking | 19 | Strecher, 2008^71^ | High depth efficacy expectation Low depth efficacy expectation | Depth of outcome expectation of smoking cessation intervention | 0
Smoking | 19 | Strecher, 2008^71^ | High depth efficacy expectation Low depth efficacy expectation | Depth of success stories of smoking cessation intervention | +
Smoking | 19 | Strecher, 2008^71^ | High depth efficacy expectation Low depth efficacy expectation | Personalization of message source | +
Smoking | 19 | Strecher, 2008^71^ | High depth efficacy expectation Low depth efficacy expectation | Timing of message exposure | 0
Smoking | 19 | Strecher, 2006^72^ | Web-based Committed Quitters Stop Smoking Plan (CQ Plan) | Tobacco related illness | +
Smoking | 19 | Strecher, 2006^72^ | Web-based Committed Quitters Stop Smoking Plan (CQ Plan) | Non-smoking children in household | +
Smoking | 19 | Strecher, 2006^72^ | Web-based Committed Quitters Stop Smoking Plan (CQ Plan) | Frequency of alcohol consumption | +
Smoking | 19 | Strecher, 2005 73 | Computer- generated tailored letter | 7-day abstinence at 12 months (intent to treat analysis) | +
Smoking | 19 | Strecher, 2005 73 | Computer- generated tailored letter | 7-day abstinence at 12 months of subjects who were abstinent at 5months (intent to treat analysis) | 0
Smoking | 19 | Strecher, 2005 73 | Computer- generated tailored letter | 7-day abstinence at 12 months of subjects who were abstinent at 5months (per protocol analysis) | +
Smoking | 19 | Strecher, 2005^74^ | CQ Plan | 28 day abstinence rate | +
Smoking | 19 | Strecher, 2005^74^ | CQ Plan | 10 week continuous rates | +
Smoking | 19 | Strecher, 1994 75 Study 1 | Computer-generated tailored letter | 7-day abstinence (all smokers) | 0
Smoking | 19 | Strecher, 1994 75 Study 1 | Computer-generated tailored letter | 7-day abstinence (light smokers) | +
Smoking | 19 | Strecher, 1994 75 Study 1 | Computer-generated tailored letter | 7-day abstinence (heavy smokers) | +
Smoking | 19 | Swartz, 2006^76^ | Received immediate access to the Web site Behavioral intervention for smoking (intent to treat model) | Cessation of smoking at 90 days | +

* (+) positive impact of the CHI application on outcome; (−) negative impact of the CHI application on outcome; (0) no impact or not a significant of the CHI application on outcome

† significance of these outcomes was not reported

‡ Study investigates internet-based intervention with addition of self-help booklet compared to internet-based intervention alone

‡ a randomized trial testing a Web-assisted cessation intervention for college smokers

AUDIT = Alcohol Use Disorders Identification Test; BAC = blood alcohol concentration; BL = baseline;

CHESS SCRP= Comprehensive Health Enhancement Support System for Smoking Cessation and Relapse Prevention; CQ Plan = committed quitters plan; DCU = Drinker’s Check-up; DL = drinking less

#### Strengths and Limitations of the Evidence

Twenty-six studies were available to evaluate CHI impact on intermediate health outcomes related to use of alcohol and tobacco. Seven studies were available to evaluate CHI impact within the context of alcohol abuse and 19 studies were available to evaluate this impact within the context of tobacco use. The sample sizes yielded appropriate power in these studies, with sample sizes ranging from 83 to 288 respondents for the alcohol abuse studies and ranging from 139 to 3971 respondents for the tobacco use studies. The overall strength of the body of this evidence (Table 8) for the effects on intermediate outcomes was graded as high for smoking cessation and high for alcohol abuse based on a modified version of the GRADE criteria5 and Chapter 11 of the EPC Manual6. It is important to note that many of the intermediate outcome measures were patient-reported.

Table 8

Grade of the body of evidence addressing CHI impact on intermediate outcomes in alcohol abuse and smoking.

1 | Protection against risk of bias bias) (relates to study design, study quality, reporting | (Alcohol abuse) High | (Smoking cessation) High
2 | Number of studies | 7 | 19
3 | Did the studies have important inconsistency? y (−1); n (0) | 0 | 0
4 | Was there some (−1) or major (−2) uncertainty about the directness or extent to which the people, interventions and outcomes are similar to those of interest? Some(−1); major (−2); none (0) | 0 | 0
5 | Were the studies sparse or imprecise? y (−1); n (0) | 0 | 0
6 | Did the studies show strong evidence of association between intervention and outcome? “strong^*^” (+1); “very strong^†^” (+2); No (0) | 0 | 0
| Overall grade of evidence ‡ | High | High

* if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders

† if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity

‡ (high, moderate, low):if above score is (+), increase grade; if above score is (−), decrease grade from high to moderate (−1) or low (−2).

#### General Study Characteristics

The studies on the impact of CHI applications on intermediate health outcomes related to use of alcohol and tobacco were generally conducted among adult, non-elderly populations. Most of the respondents in these studies were under 40 years of age, although the mean age range of participants across studies was 18–70 years of age. Five studies 50–54 specifically targeted either adolescents or young adults (age range 11–26 years). Information regarding gender suggested that female participants represented a little over half of the study population. When reported, the race/ethnicity of respondents was generally Caucasian, with smaller percentages of Asian, Native American, African-American or Black, or other groups participating. Educational level and marital status was variable across studies. (Appendix G, Evidence Tables 11, 12, 14, 15).

#### Outcomes

##### Alcohol abuse

Riper et al58 investigated the effects of a Web-based, multi-component, interactive self-help intervention for problem drinkers without therapist guidance compared to a control intervention consisting of receiving access to an online psychoeducational brochure on alcohol use. Based on complete case analysis, the intervention group decreased their mean weekly alcohol consumption significantly more than the control group (p=0.001). In a subsequent secondary analysis of data from this study the authors demonstrated that at six and 12 month follow up women and those with higher levels of education were more likely to have lower alcohol consumption levels, based on self report, as compared to controls.59 (Appendix G, Evidence Table 13).

Lieberman57 investigated program adherence to an online alcohol-use evaluation among study participants. After completing four standard questionnaires to evaluate problem drinking, an intervention consisting of a multimedia condition involving a personified guide was compared with a control treatment of feedback from the questionnaire results in text form. Increased levels of program adherence, as assessed by completion of greater numbers of modules of the online alcohol-use evaluation, were more strongly associated with the multimedia feedback via the personified guide (p<0.01) (Appendix G, Evidence Table 13).

Cunningham et al55 investigated the effects of an Internet-based personalized feedback intervention compared to the same intervention with the addition of a self-help book based on three outcomes: mean typical number of drinks per week, mean Alcohol Use Disorders Identification Test (AUDIT) scores, and mean number of alcohol consequences experienced. Study participants who received the additional self-help book reported decreased consumption of alcoholic drinks per week (p<0.05), a lower AUDIT score (p<0.05), and fewer alcohol-related consequences (p<0.05) compared to participants who received the Internet-based intervention alone (Appendix G, Evidence Table 13).

Hester et al56 investigated the effect a computer-based brief motivational intervention, the Drinker’s Checkup (DCU). The intervention was randomly assigned to participants in either an immediate treatment group or to a 4-week Delayed Treatment group and participants were followed over a 12-month period. Significant effects were reported for the Immediate group when comparing baseline measurement to measurement at 12 months for the outcomes of average drinks per day and average peak blood alcohol content (BAC) (p=0.002 and p=0.001, respectively). For the Delayed group, significant effects were also reported when comparing baseline measurement to measurement at 12 months for the outcomes of average drinks per day and average peak BAC (p=0.008 and p=0.003, respectively). Significance was not reported for the outcome of drinks per drinking day for either the Immediate or Delayed Treatment groups (Appendix G, Evidence Table 13).

Kypri et al51 investigated the effects 10–15 minutes of Web-based assessment and personalized feedback for hazardous drinking as compared with a control treatment of an informational leaflet only. Six outcomes were measured at 6 weeks and 6 months: frequency of drinking; typical occasion quantity; total consumption; frequency of very episodic heavy drinking; personal, social, sexual, and legal consequences of episodic heavy drinking; and consequences related to academic performance. Significant effects of the intervention were seen on outcomes of total consumption at 6 weeks (p=0.03); frequency of very episodic heavy drinking at 6 weeks (p=0.02); and personal, social, sexual, and legal consequences of episodic heavy drinking at both 6 weeks and 6 months (p=0.01 and p=0.03, respectively). No significant effects of the intervention on other outcomes were demonstrated (Appendix G, Evidence Table 13).

Neighbors et al 52 investigated the effects of a computer-delivered personalized normative feedback intervention in decreasing alcohol consumption among heavy-drinking college students. Outcomes assessed were effect size in perceived norms and the effect size in reduction in alcohol consumption. The effect size for the intervention effect on drinking was reported to be significant at 3 and 6 months (p<0.01). Significance of the effect size for the intervention effect on perceived norms was not reported.

##### Smoking cessation

When evaluating behavior change regarding smoking cessation, An et al. 53 found that an online college life magazine providing personalized smoking cessation messages and peer email support (the RealU intervention) was associated with a higher self-reported 30-day abstinence rate among college smokers when compared to a control group (p<0.001) . There was no difference reported between study groups for self-reported 6-month prolonged abstinence, however (Appendix G, Evidence Table 16).

Strecher et al71 evaluated the effectiveness of web-based smoking cessation programs with experimentally manipulated depth of tailoring. The research team used the term “tailoring” to refer to a process consisting of 1) assessment of individual characteristics relevant to smoking cessation, 2) algorithms that use the assessment data to generate intervention messages relevant to the specific needs of the user, 3) a feedback protocol that delivers these messages to the participant in a clear format. The intervention was a web-based smoking cessation program plus nicotine patch with use of tailoring depth of the intervention based on five randomized components: high- versus low-depth tailored success story, outcome expectation, efficacy expectation messages, high- versus low-personalized source, and multiple versus single exposure to the intervention components. Although depth of tailoring with a web-based smoking cessation program plus nicotine patch was shown to influence rates of point-prevalence abstinence at 6-month follow-up, results were most significant for high- versus low-depth success story (p<0.018) and high- versus low-personalization of message (p<0.039) (Appendix G, Evidence Table 16).

In another study, Strecher et al72 investigated the effects of a web-based computer-tailored smoking cessation program (CQ Plan) as compared to an intervention of nontailored web-based cessation materials (CONTROL) among nicotine patch users. Significant effects for increased rates of ten-week continuous abstinence at 12 week follow-up were seen with the CQ Plan intervention when the study groups were stratified according to presence or absence of tobacco-related illness (p<0.001 and p<0.05, respectively), presence or absence of non-smoking children in the household (p<0.001 and p<0.10, respectively), and frequency of alcohol consumption of greater than three times per week as compared to less than three times per week among participants (p<0.001 and p<0.10, respectively) (Appendix G, Evidence Table 16).

A third study by Strecher et al 74 found that an intervention of web-based tailored behavioral smoking cessation materials was more effective than a control of web-based non-tailored materials. Outcomes of 28-day continuous abstinence rates at 6 weeks and 10-week continuous abstinence rates at 12 weeks were more strongly associated with the intervention group (p<0.008 and p<0.0004, respectively) (Appendix G, Evidence Table 16).

Strecher et al75 also evaluated the impact of computer tailored smoking cessation letters on smoking cessation behaviors among a group patients (n=51) recruited from a family practice clinic in North Carolina. At four month follow up smoking cessation rates differed significantly in the computer tailored group among patients who smoked less than 1 pack per day (p<0.05). No difference was seen among those who smoked more than 1 pack per day. In a similar study of a larger sample (n=1484) reported in the same paper again found significantly higher smoking cessation rates at 6 months follow up only among those who smoked less than one pack per day (p<0.05) (Appendix G, Evidence Table 16).

One additional study by Strecher et al73 evaluated the efficacy of adding computer tailored letters to an established telephone based smoking cessation intervention. At 12 month follow up, the intervention failed to produce any additional impact on smoking cessation rates as compared to quitline only controls.

Severson et al. 67 found that an interactive, tailored web-based intervention (Enhanced Condition) when compared to a more linear, text-based website (Basic condition) was more effective for cessation of all forms of tobacco use as well as specifically for smokeless tobacco use at 3 and 6 months (p<0.001) (Appendix G, Evidence Table 16).

Schumann et al.70 investigated a computer-tailored transthoretical model-based smoking cessation intervention in a general population setting in Germany and found the intervention to be ineffective (Appendix G, Evidence Table 16).

Japuntich et al.64investigated an internet-based intervention as an adjuvant treatment in a smoking cessation program as compared to a control group of pharmaceutical treatment and counseling alone and did not find significant intergroup effects (Appendix G, Evidence Table 16).

Patten et al.54 found an internet-based intervention when compared to a brief office intervention did not produce significant treatment differences for smoking abstinence rates among adolescent study participants (Appendix G, Evidence Table 16).

Swartz et al 76investigated a video-based internet site presenting strategies for smoking cessation and motivational materials tailored to the user’s race/ethnicity, sex, and age. Rates of abstinence at 90-day follow-up were measured for participants using this intervention and compared with abstinence rates among participants using the control intervention of a 90-day wait period prior to accessing the internet program. Greater abstinence rates were associated with the intervention group as compared to the control group, using both complete case analysis (p<0.002) as well as intent-to-treat analysis (p<0.015). (Appendix G, Evidence Table 16).

Shiffman et al.68 investigated the effects of computer-tailored materials offered to purchasers of nicotine polacrilex gum in the Committed Quitters Program (CQP) compared to the use of a brief untailored user’s guide and audiotape in the starter package of the nicotine polacrilex gum . Outcomes of 28-day continuous abstinence rates at 6 weeks and 10-week continuous abstinence rates at 12 weeks were more strongly associated with the intervention group (p<0.001) (Appendix G, Evidence Table 16).

Dijkstra et al.62 evaluated the efficacy of computerized smoking cessation messages that were either personalized, adapted or provided with personal feedback on smoking cessation rates at four months. Results of this investigation indicate that significantly higher rates of cessation were achieved in the personalization and feedback groups as compared to controls (p>0.05) (Appendix G, Evidence Table 16).

Hang et al77 investigated the value of using individualized text messaging (short message service (SMS) for continuous individual support of smoking cessation among young adults. Post intervention analysis revealed no significant effect of text messaging on smoking behavior (Appendix G, Evidence Table 16).

Brendryen et al60 sought to evaluate a multicomponent, one year smoking cessation intervention delivered via the Internet and cell phone and consisting of email contacts, Web pages, interactive voice response, text messaging technology and a craving telephone helpline. The results indicate that the intervention group achieved statistically significantly higher abstinence rates than control participants (20 percent versus 7 percent, odds ratio [OR] = 3.43, 95 percent CI = 1.60–7.34, p=0.002) (Appendix G, Evidence Table 16).

Prokhorov et al66 evaluated the long term efficacy of a CD ROM based smoking initiation prevention program among urban inner city adolescents. The CD ROM contained embedded animations, video, and interactive activities and was composed of five weekly sessions in one semester and two “booster” sessions in the following semester (each 30 min in duration). At the beginning of each session, students were given a series of activities that were tailored to their stage of intention and designed to promote smoking cessation or reduced likelihood of initiation (for nonsmokers). At 18-month follow-up, smoking initiation rates were significantly lower in the intervention group compared to control (1.9 percent vs. 5.8 percent, p=0.05) (Appendix G, Evidence Table 16).

Schumann et al69 evaluated a CHI application that involved up to 3 individualized feedback letters generated by special computerized expert-system software and additional stage-tailored self-help booklets. This intervention failed to demonstrate any significant effect on smoking rates (Appendix G, Evidence Table 16).

Prochaska et al65 compared standardized self-help manuals, individualized manuals, an interactive computer system plus individualized manuals or personalized counselor calls plus manuals. As compared to the standardized self help manual control group the interactive computer group had a significantly larger impact on point prevalence abstinence than all other groups at 6 months (p<0.05), 12 months (p<0.05) and 18 months (p<0.05). The interactive computer group also significantly improved prolonged abstinence rates at 18 months (p<0.05) (Appendix G, Evidence Table 16).

Schneider 78 et al) tested the efficacy of an online personalized, comprehensive behavioral smoking cessation forum offered through a commercial computer networking business. The intervention was an asynchronous chat/discussion group moderated by a psychologist, a psychiatrist, and a lay ex-smoker. The results of this investigation indicated that the intervention did not significantly improve smoking cessation rates as compared to no intervention controls.

Curry et al61 compared the efficacy three treatments on smoking cessation behavior: a self-help booklet alone; a self-help booklet with computer-generated personalized feedback; and a self-help booklet, personalized feedback, and outreach telephone counseling. Salivary cotinine levels were obtained to validate self reports at 12 month follow up. At three month follow up only the telephone counseling group achieved significantly higher 7 day cessation rates as compared to controls (p=0.02) (Appendix G, Evidence Table 16).

### Obesity

#### Summary of the Findings

Eleven studies evaluated the impact of CHI applications on intermediate outcomes related to obesity (Table 9). The studies mostly addressed middle-class consumers across the United States (US) and United Kingdom (UK), while one study targeted lower socioeconomic status school children. The interventions often employed online, Web based technical platforms. In addition, one study employed a pocket computer device and another used a laptop computer. No application had a large effect on improving weight-loss behavior, weight change, or body composition. The quality of the studies investigating obesity was variable with Jadad study quality scores 4 ranging from moderately high (one study) to low. (Appendix G, Evidence Table 1)

Table 9

Results of studies on CHI applications impacting intermediate outcomes related to obesity (N=11).

Target condition | N | Author, year | Interventions | Primary outcomes measured | Effect of CHI Applications^*^
Obesity | 11 | Booth, 2008^87^ | On-line weight reduction program including dietary advice plus exercise Exercise only program | Weight change | +
Obesity | 11 | Booth, 2008^87^ | On-line weight reduction program including dietary advice plus exercise Exercise only program | Waist circumference change | 0
Obesity | 11 | Booth, 2008^87^ | On-line weight reduction program including dietary advice plus exercise Exercise only program | Physical activity | 0
Obesity | 11 | Booth, 2008^87^ | On-line weight reduction program including dietary advice plus exercise Exercise only program | Energy intake | 0
Obesity | 11 | Burnett-Kent, 1985^90^ | Computer Assisted method of providing feedback | Short term weight change: Baseline 2 wk period | 0
Obesity | 11 | Burnett-Kent, 1985^90^ | Computer Assisted method of providing feedback | Short term weight change: Post-baseline 8 wk period | +
Obesity | 11 | Burnett-Kent, 1985^90^ | Computer Assisted method of providing feedback | Long term weight changes (24 wks) | +
Obesity | 11 | Burnett-Kent, 1985^90^ | Computer Assisted method of providing feedback | Long term weight changes (40 wks) | +
Obesity | 11 | Burnett-Kent, 1985^90^ | Computer Assisted method of providing feedback | Self-reported Caloric intake | +
Obesity | 11 | Burnett-Kent, 1985^90^ | Computer Assisted method of providing feedback | Self-reported physical activity | +
Obesity | 11 | Cussler, 2008^86^ | Internet group | Weight change | 0
Obesity | 11 | Cussler, 2008^86^ | Internet group | BMI | 0
Obesity | 11 | Cussler, 2008^86^ | Internet group | Exercise energy expenditure | 0
Obesity | 11 | Cussler, 2008^86^ | Internet group | Energy intake | 0
Obesity | 11 | Frenn, 2005^88^ | Internet based interactive model | Physical Activity | +
Obesity | 11 | Frenn, 2005^88^ | Internet based interactive model | Diet | +
Obesity | 11 | Hunter, 2008^‡,85^ | Behavioral Internet treatment(BIT) | Body weight | +
Obesity | 11 | Hunter, 2008^‡,85^ | Behavioral Internet treatment(BIT) | BMI | +
Obesity | 11 | Hunter, 2008^‡,85^ | Behavioral Internet treatment(BIT) | Waist circumference | +
Obesity | 11 | Hunter, 2008^‡,85^ | Behavioral Internet treatment(BIT) | Body fat percentage | +
Obesity | 11 | Kroeze, 2008^†,80^ | Interactive - tailored condition Print - tailored condition | Total fat intake | +
Obesity | 11 | Kroeze, 2008^†,80^ | Interactive - tailored condition Print - tailored condition | Saturated fat intake | 0
Obesity | 11 | Kroeze, 2008^†,80^ | Interactive - tailored condition Print - tailored condition | Energy intake | +
Obesity | 11 | McConnon, 2007^81^ | Internet intervention | BMI change at 12 months | 0
Obesity | 11 | McConnon, 2007^81^ | Internet intervention | Loss of 5% or more body weight (12 months) | 0
Obesity | 11 | Morgan , 2009^91^ | Internet-based weight-loss program | Physical activity (mean steps/day) 3 months | +
Obesity | 11 | Morgan , 2009^91^ | Internet-based weight-loss program | Physical activity (mean steps/day) 6 months | +
Obesity | 11 | Morgan , 2009^91^ | Internet-based weight-loss program | Energy intake (kJ/day) 3 months | +
Obesity | 11 | Morgan , 2009^91^ | Internet-based weight-loss program | Energy intake (kJ/day) 6 months | +
Obesity | 11 | Taylor, 1991^89^ | Computer Assisted Therapy | Weight Loss (Post-treatment 12weeks – Pretreatment) | 0
Obesity | 11 | Taylor, 1991^89^ | Computer Assisted Therapy | Weight Loss (followup at 6 months – Pretreatment) | 0
Obesity | 11 | Williamson, 2006^§,83^ | Interactive nutrition education program and Internet counseling behavioral therapy for the intervention group | Body weight | +
Obesity | 11 | Williamson, 2006^§,83^ | Interactive nutrition education program and Internet counseling behavioral therapy for the intervention group | Body composition | +
Obesity | 11 | Williamson, 2006^§,83^ | Interactive nutrition education program and Internet counseling behavioral therapy for the intervention group | Weight loss behavior | 0
Obesity | 11 | Williamson, 2006^§,83^ | Interactive nutrition education program and Internet counseling behavioral therapy for the intervention group | BMI | +
Obesity | 11 | Womble, 2004\|\|84 | ediets.com | Weight change percent | −
Obesity | 11 | Womble, 2004\|\|84 | ediets.com | Weight change (kg) | −

* (+) positive impact of the CHI application on outcome; (−) negative impact of the CHI application on outcome; (0) no impact or not a significant of the CHI application on outcome

† positive impacts (where indicated) only at 3months post-intervention, at 6 months post-intervention all impacts were insignificant

‡ A positive impact indicates a decrease in any of the four listed outcomes

§ positive impacts (where indicated) only at 12 months post-intervention, at 24 months post-intervention all impacts were insignificant

|| A negative impact indicates an increase in any of the two listed outcomes

BMI=body mass index; kJ/day = kilojoules per day; kg = kilogram; wk = week

Several studies employed Internet-based technical platforms while one study employed a pocket computer device and another utilized a laptop computer. Educational content used in the applications was custom designed by the investigators based on a range of Theoretic models: Precaution Adoption Process Model Theory of Planned Behavior,79,80 evidence from obesity research,81 and behavioral family-based treatment.82,83 Other sites listed their features: social support,84 ethnic-related sources,83 or self-monitoring food exercises85 (Appendix G, Evidence Tables 17–19). The overall strengths of the body of this evidence (Table 10) was graded as moderate based on a modified version of the GRADE criteria5 and Chapter 11 of the EPC Manual.6

Table 10

Grade of the body of evidence addressing CHI impact on intermediate outcomes in obesity.

1 | Protection against risk of bias (relates to study design, study quality, reporting bias) | High
2 | Number of studies | 11
3 | Did the studies have important inconsistency? y (−1); n (0) | 0
4 | Was there some (−1) or major (−2) uncertainty about the directness or extent to which the people, interventions and outcomes are similar to those of interest? Some (−1); major (−2); none (0) | 0
5 | Were the studies sparse or imprecise? y (−1); n (0) | −1
6 | Did the studies show strong evidence of association between intervention and outcome? “strong^*^” (+1); “very strong^†^” (+2); No (0) | 0
| Overall grade of evidence ‡ | Moderate

* if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders

† if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity

‡ (high, moderate, low):if above score is (+), increase grade; if above score is (−), decrease grade from high to moderate (−1) or low (−2).

#### Strengths and Limitations of the Evidence

Eleven studies evaluated several domains of CHI impact on obesity. Enrolled study participants included adults (18–65) 80 middle-aged consumers81,84–87 teenagers, 83 school aged adolescents,88 overweight women89,90 and overweight/obese men.91 Several studies were restricted to consumers already obese on the basis of body mass index (BMI).80 In terms of race/ethnicity,81,83–86 studies enrolled American populations, European,91 British81 and Dutch80 consumers. One study targeted African-Americans83 and another targeted primarily African-Americans and Hispanics88 (Appendix G, Evidence Tables 17–19).

#### General Study Characteristics

Across studies, the average age of enrolled consumers was early 40s. Williamson et al83 however, recruited teens with an average age of 13 years (SD 1.4), and Frenn88 recruited middle-school seventh graders aged 12–14. Five studies80,88–90 targeted either predominately female or only female consumers. One study targeted only males. 91 In terms of educational levels, the Kroeze et al80 study included participants who had the following distribution of educational attainment (tertiary 42 percent, higher secondary 37 percent, the remainder below that). A study by Hunter et al enrolled mostly Caucasian participants while Frenn’s study enrolled approximately 30 percent African-American and 30 percent Hispanics (Appendix G, Evidence Tables 17 and 18).

#### Outcomes

##### Weight-loss behavior

Williamson et al83 presented graphs on dieting change, exercise change, overeating change, and avoidance of fat food change, none of which favored the intervention, in either the teens or their parents. Cussler et al86 similarly showed equivalent exercise energy expenditure in controls (mean164 [kcal/day], SD 268[kcal/day]) and interventions (mean 123 [kcal/day], SD 265 [kcal/day]) and equivalent change in energy intakes of 91 kcal/day (SD 33) and 74 kcal/day (SD 371) in the two groups, respectively. Kroeze and colleagues80 measured food intake and found a decrease at 1 month equal to or greater than the effect of a printed resource. For instance, for total fat intake, the regression-coefficient confidence intervals (CIs) were (−18.6, −3.23) and (−15.59, −0.04) respectively. There were similar effects for saturated fat and energy. The effects were statistically indistinguishable from 0 at 6 months. Print resources were more effective for high-risk consumers, with effects lasting 6 months, and with the Internet group showing no statistically significant improvement. Booth et al87 measured weight-loss behavior through changes in physical activity (number of steps counted per day) and changes in energy intake. Both the exercise-only and the online exercise and diet advice groups showed a significant increase in the number of daily steps taken. Both groups showed a decrease in energy intake at the 12-week measuring period, but the differences were not significant. Frenn et al 88 demonstrated a significant improvement in physical activity and significant reductions in dietary fat intake from an 8-session interactive Web-based intervention (p=0.05). Burnett-Kent et al90 found that a laptop based computer assisted therapy system could enable participants to achieve a significantly higher mean weight loss at 8 week follow up (p<0.05) as compared to controls not using the computer assisted therapy system. The effect size was reported to be r_m_ =0.75. The significant enhancement of weight loss by the computer assisted therapy was also found at 24 and 40 months (p<0.2 and p<0.5 respectively). Effect sizes were not reported for these longer term findings. The computer system did not have a significant effect on self-reported caloric intake and physical activity. Finally Morgan et al91 demonstrated a significant increase in physical activity and significant reductions in energy intake as compared to baseline in both the Internet based program and information session and program booklet as well as the information session and program-booklet-only control group at the 6-month followup (Appendix G, Evidence Table 19).

##### Weight change

Cussler et al86 showed no difference in weight change: 1 kg (SD 4.6) loss for control, 0.7 kg (5.4) loss for the intervention. Hunter et al85 documented a statistically significant difference in BMI change: in the internet group , a decrease of 1.3 kg/m^2^ at 6 months, with an increase in the control groups of 0.5 kg/m^2^ (initial BMI ≥ 27 kg/m^2^) and 0.9 kg/m^2^ (initial BMI ≤ 27 kg/m^2^) (p value not stated). Womble et al84 reported percent change in weight from baseline. Again, the effects were small (1–4 percent), with overlapping confidence intervals. Four studies reported BMI changes. Cussler et al86 reported identical changes of 2 kg/m^2^ at 4 and at 16 months. Hunter et al85 also showed no change in BMI at 6 months (change statistically indistinguishable from 0 and overlapping CIs). McConnon et al81 reported a mean change of 0.3 kg/m^2^ (CI −0.5 to 1 kg/m^2^, p=0.4) in favor of the Internet intervention, but not statistically significant. Williamson et al83 also found a change of about 1 kg/m^2^ for the two groups (1.2 kg/m^2^ loss for the control group, 0.73 kg/m^2^ loss for the intervention group, statistically not significantly different from each other) that became statistically nonsignificant at 18 months. Booth 87 reported that weight change in the exercise-only group had a higher percentage weight loss than online diet and exercise program group at 12 weeks; the difference between the two groups was not significant. Taylor et al89 found no effect of a computer-assisted therapy application on weight loss at 12 weeks or at the 6-month followup. Finally, Morgan et al91 found significant increases in weight loss from baseline in the Internet-based program and information session and program booklet as well as the information session and program-booklet-only control group at the 6-month followup (Appendix G, Evidence Table 19).

##### Body composition

Hunter et al85 reported on body fat percentages. These, too, showed no difference between the control group (mean 34.7, SD 7.0) and the intervention group (mean 33.9, SD 7.3) at 6 months. Similarly, Williamson and colleagues83 reported an increase in body fat, as measured by dual-energy x-ray absorptiometry (DXA), of 0.84 percent (SD 0.72) for the control group and a decrease of 0.08 percent (SD 0.71) for the intervention group. Results of the Booth study87 found the exercise-only group had a greater change in waist circumference, but the difference between the two groups was not significant. Finally, Morgan et al demonstrated significant changes in body weight, waist circumference, and BMI as compared to baseline in both the Internet-based program plus information session and program booklet as well as the information session and program-booklet-only control group at the 6-month followup (Appendix G, Evidence Table 19).

### Diabetes

#### Summary of Findings

Seven studies examined the effect of a CHI application on intermediate outcomes such as health knowledge and health behavior in people with diabetes mellitus (Table 11). One of the seven studies also included patients with heart disease and chronic lung disease. All studies were RCTs, but the studies had low study quality scores and did not always directly address one of our key questions. The findings were inconsistent across studies regarding the impact of a CHI application on intermediate outcomes related to diabetes, with four studies suggesting a benefit in terms of self-care, knowledge, physical activity adherence and satisfaction and three other studies indicating mostly a lack of benefit (Appendix G, Evidence Table 1).

Table 11

Results of studies on CHI applications impacting intermediate outcomes in diabetes (N=6).

Target condition | N | Author, year | Interventions | Primary outcomes measured | Effect of CHI applications^*^
Diabetes | 6 | Glasgow, 2003^97^ | Tailored self-management | Kristal Fat and Fiber Behavior scale | −
Diabetes | 6 | Homko, 2007^92^ | Telemedicine | Self-efficacy (Diabetes Empowerment Scale (DES)) | +
Diabetes | 6 | Homko, 2007^92^ | Telemedicine | Satisfaction and readiness to change | +
Diabetes | 6 | McKay, 2001^95^ | Internet-based physical activity intervention | Moderate-to-vigorous exercise | 0
Diabetes | 6 | McKay, 2001^95^ | Internet-based physical activity intervention | Walking | 0
Diabetes | 6 | Richardson, 2007^39^ | Computerized feedback mechanism | Total Step | +
Diabetes | 6 | Richardson, 2007^39^ | Computerized feedback mechanism | Bout Steps | +
Diabetes | 6 | Richardson, 2007^39^ | Computerized feedback mechanism | Satisfaction | +
Diabetes | 6 | Richardson, 2007^39^ | Computerized feedback mechanism | Usefulness | +
Diabetes | 6 | Richardson, 2007^39^ | Computerized feedback mechanism | Adherence (Likelihood of wearing a pedometer) | +
Diabetes | 6 | Richardson, 2007^39^ | Computerized feedback mechanism | Adherence (Mean hours of wearing a pedometer) | +
Diabetes | 6 | Wangberg, 2006^†,93^ | Low self-efficacy High self-efficacy | Summary of Diabetes Self Care Activities | +
Diabetes | 6 | Wangberg, 2006^†,93^ | Low self-efficacy High self-efficacy | Perceived competence scale | −
Diabetes | 6 | Wangberg, 2006^†,93^ | Low self-efficacy High self-efficacy | Minutes activity per day | 0
Diabetes | 6 | Wise, 1986^94^ | Interactive computer assessment | Knowledge score | +
Diabetes with with heart disease and chronic lung disease | 1 | Lorig, 2006^‡,96^ | Online intervention | Change in health distress (0–5) | +
Diabetes with with heart disease and chronic lung disease | 1 | Lorig, 2006^‡,96^ | Online intervention | Change in self-reported global health(0–5) | 0
Diabetes with with heart disease and chronic lung disease | 1 | Lorig, 2006^‡,96^ | Online intervention | Change in illness intrusiveness | 0
Diabetes with with heart disease and chronic lung disease | 1 | Lorig, 2006^‡,96^ | Online intervention | Change in self-efficacy | 0

* (+) positive impact of the CHI application on outcome; (−) negative impact of the CHI application on outcome; (0) no impact or not a significant of the CHI application on outcome

† study compares CHI targeting low self-efficacy items with CHI targeting high self-efficacy items: (+) indicates that there was an increase in self efficacy in both groups; (−) indicates a decrease in both groups

‡ study measures the use of a personal monitoring device with tailored self –management compared with no tailored self-management

#### Strengths and Limitations of the Evidence

Seven studies evaluated a wide range of effects of CHI applications on intermediate outcomes related to diabetes (Appendix G, Evidence Tables 20–22). All studies were RCTs, but the comparisons being made were not all directly relevant to our key question. All seven of the studies received low to very low study quality scores. This is a result of the difficulty in blinding participants, and often investigators, regarding the assignment to the control and intervention groups. Additionally, one study did not explain withdrawals.4 The overall strength of the body of this evidence (Table 12) was graded as low based on a modified version of the GRADE criteria5 and Chapter 11 of the EPC Manual.6

Table 12

Grade of the body of evidence addressing CHI impact on intermediate outcomes in diabetes.

1 | Protection against risk of bias (relates to study design, study quality, reporting bias) | Moderate
2 | Number of studies | 6
3 | Did the studies have important inconsistency? y (−1); n (0) | −1
4 | Was there some (−1) or major (−2) uncertainty about the directness or extent to which the people, interventions and outcomes are similar to those of interest? Some (−1); major (−2); none (0) | −1
5 | Were the studies sparse or imprecise? y (−1); n (0) | 0
6 | Did the studies show strong evidence of association between intervention and outcome? “strong^*^” (+1); “very strong^†^” (+2); No (0) | 0
| Overall grade of evidence ‡ | Low

* if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders

† if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity

‡ (high, moderate, low):if above score is (+), increase grade; if above score is (−), decrease grade from high to moderate (−1) or low (−2).

#### General Study Characteristics

Four of the studies were limited to type 2 diabetes, one was limited to gestational diabetes,92 and two included both type 1 and type 2 diabetes.93,94 Four of the studies evaluated an interactive consumer Web site,92,93,95,96 two evaluated a personal monitoring and feedback device,39,97 Another study evaluated an interactive computer program.94 Comparisons were generally made between a control group and an intervention group that was exposed to a CHI application. However, in the study by Wangberg,93 both groups received an Internet-based intervention, with one group receiving an intervention targeted at the area of self-care for which reported self-efficacy was lowest, and the other group receiving an intervention targeted at the area of self-care for which reported self-efficacy was highest (Appendix G, Evidence tables 20 and 21).

#### Outcomes

##### Self-efficacy, self-care, and self-management

Homko et al evaluated the feasibility of monitoring glucose control in indigent women with gestational diabetes mellitus (GDM) over the Internet. Women with GDM were randomized to either the Internet group (n=32) or the control group (n = 25). Patients in the Internet group were provided with computers and/or Internet access if needed. A Web site was established for documentation of glucose values and communication between the patient and the health care team. Women in the control group maintained paper logbooks. The results of this study indicate that women in the Internet group demonstrated significantly higher feelings of self-efficacy at the study’s end 92 (Appendix G, Evidence Table 22).

In the Wangberg study,93 the author assessed whether self-efficacy(SE) could function as a moderator of the effect of a tailored Internet-based intervention aimed at increasing self-reported diabetes self-care behaviors. There was a significant overall main effect of the intervention on self-care, F(1,25) = 5.56, p=0.026. A significant interaction between change in self-care and baseline self-efficacy was found, F(1,25) = 4.67, p=0.040, with lower baseline self-efficacy being related to greater improvements in self-care. A significant interaction between time and gender was observed, F(1,25) = 4.78, p=0.038, with men having greater improvements in self-care than women93 (Appendix G, Evidence Table 22).

Lorig et al96 evaluated the impact on self-efficacy of an Internet-based tailored chronic disease self-management program. The results indicate that the intervention group increased their self-efficacy significantly more than controls (0.40 [SD 1.98] p=0.051) This study also found that the mean Health Distress Score decreased significantly more in the intervention group (0.377 [SD 1.11] p=0.013) compared to controls96

Wise et al94 compared the effects of an interactive computer program, graphic animations and personalized feedback vs. knowledge assessment and printed feedback vs. knowledge assessment alone on knowledge and insulin control among insulin dependant and non insulin dependant diabetics (IDDM and NIDDM respectively). Among IDDM patients at 4–6 month follow up the printed feedback group and the computer program group showed significant increased in knowledge (p<0.05 and p<0.01 respectively). The same was also true among NIDDM patients (0<0.1 and p<0.05 respectively). In terms of glucose control all three treatment groups resulted in significant reductions in HbA1c (knowledge assessment only [9.1± 0.2 percent to 8.4±0.1 percent, p<0.05], knowledge assessment and feedback [9.3±to 8.1±0.4 percent, p<0.05] and interactive computer program [9.3±0.2 percent to 8.6±0.3 percent, p<0.05 percent]). Finally among NIDDM patients significant reductions in HbA1c were only seen in the knowledge assessment group and the feedback groups (knowledge assessment [9.6±0.4 percent to 8.8±0.3 percent, p<0.05] and feedback [9.2±0.4 percent to 7.9±0.4 percent, p<0.01]) (Appendix G, Evidence Table 22).

##### Physical activity

McKay et al95 evaluated an Internet-based supplement (D-Net) to usual care that focused on providing support for sedentary patients with type 2 diabetes to increase their physical activity levels. The intervention group received goal-setting and personalized feedback, identified and developed strategies to overcome barriers, received and could post messages to an online “personal coach,” and were invited to participate in peer group support areas. Results of this intervention indicate a significant increase in moderate to vigorous physical activity (minutes/day) (p<0.001) and walking (minutes/day) (p<0.001).95 In a 10-month followup evaluation of the McKay intervention (D-Net), the data indicate significant improvements in the intervention group for physical activity (p<0.000)97 (Appendix G, Evidence Table 22).

A study by Richardson39 evaluated a pedometer hooked up to interactive computer-based feedback. The study failed to demonstrate an effect on actual steps taken, but did demonstrate a significant effect on patient satisfaction (p=0.006), usefulness (p=0.03), likelihood of wearing a pedometer (p=<0.001), and mean hours of wearing a pedometer (p=0.038) (Appendix G, Evidence Table 22).

##### Dietary habits

Glasgow et al97reports on additional dietary outcomes using the D-Net intervention described by McKay et al above. 10 month follow up evaluation of the intervention indicate significant improvements on the Kristal Fat and Fiber Behavior (FFB) scale (P<0.000), in daily dietary fat consumption (p<0.000), CES-D Depression scale scores (p<0.000), total cholesterol (p<0.000), LDL cholesterol (p<0.000), triglycerides (p<0.000) and Lipid ratios (p<0.000). The intervention did not significantly improve HDL cholesterol or HbA1c levels. (Appendix G, Evidence Table 22).

### Mental Health

#### Summary of the Findings

Eight studies evaluated the impact of CHI applications on intermediate outcomes in mental health (Table 13). Studies evaluated the impact of CHI on three broad aspects of mental health. These included: 1) depression/anxiety, 2) phobia, and 3) stress. Across the three domains of mental health, the scientific evidence suggested that CHI applications may have a beneficial effect on depression/anxiety, phobias, and stress (Table 14, and Appendix G, Evidence Tables 23–25).

Table 13

Results of studies on CHI applications impacting intermediate outcomes of mental health (N=8).

Target condition | N | Author, year | Interventions | Primary outcomes measured | Effect of CHI applications
Depression/anxiety | 4 | Christensen, 2004^99^ | Blue Pages: Web site MoodGYM: Computer based CBT | Center for Epidemiologic depression scale | +
Depression/anxiety | 4 | Christensen, 2004^99^ | Blue Pages: Web site MoodGYM: Computer based CBT | Automatic thoughts | +
Depression/anxiety | 4 | Christensen, 2004^99^ | Blue Pages: Web site MoodGYM: Computer based CBT | Medical literacy | +
Depression/anxiety | 4 | Christensen, 2004^99^ | Blue Pages: Web site MoodGYM: Computer based CBT | Psychological literacy | +
Depression/anxiety | 4 | Christensen, 2004^99^ | Blue Pages: Web site MoodGYM: Computer based CBT | Lifestyle literacy | +
Depression/anxiety | 4 | Christensen, 2004^99^ | Blue Pages: Web site MoodGYM: Computer based CBT | Cognitive behavior therapy literacy | +
Depression/anxiety | 4 | Neil, 2009^106^ | MoodGYM internet-based CBT | Warpy thoughts score
Depression/anxiety | 4 | Neil, 2009^106^ | MoodGYM internet-based CBT | No. of exercises completed (0—28) | +
Depression/anxiety | 4 | Proudfoot, 2004^98^ | Computerized Therapy | Depression (BDI) | +
Depression/anxiety | 4 | Proudfoot, 2004^98^ | Computerized Therapy | Anxiety (BAI) | +
Depression/anxiety | 4 | Proudfoot, 2004^98^ | Computerized Therapy | Work and Social Adjustment scale | +
Depression/anxiety | 4 | Proudfoot, 2004^98^ | Computerized Therapy | ASQ,CoNeg | +
Depression/anxiety | 4 | Proudfoot, 2004^98^ | Computerized Therapy | ASQ,CoPos | +
Depression/anxiety | 4 | Warmerdam, 2008^107^ | Interactive computer tool based on CBT | Depression (CES – D) | +
Depression/anxiety | 4 | Warmerdam, 2008^107^ | Interactive computer tool based on CBT | Anxiety using HADS | +
Depression/anxiety | 4 | Warmerdam, 2008^107^ | Interactive computer tool based on CBT | QoL using EQ5D | +
Depression/anxiety | 4 | Warmerdam, 2008^107^ | Interactive computer tool based on CBT | Depression (CES – D) Proportion reaching clinically significant change | 0
Phobia | 1 | Schneider, 2005^108^ | Computer aided cognitive behavior therapy with self-help exposure | Main Problem(self-rating) | +
Phobia | 1 | Schneider, 2005^108^ | Computer aided cognitive behavior therapy with self-help exposure | Main Goal(self-rating) | +
Stress | 2 | Chiauzzi, 2008^101^ | MyStudent Body–Stress | Perceived Stress Scale | 0
Stress | 2 | Hasson, 2005^100^ | Web-based stress management system | Self-rated stress management | +
Stress | 2 | Hasson, 2005^100^ | Web-based stress management system | Self rated sleep quality | +
Stress | 2 | Hasson, 2005^100^ | Web-based stress management system | Self rated mental energy | +
Stress | 2 | Hasson, 2005^100^ | Web-based stress management system | Self rated concentration ability | +
Stress | 2 | Hasson, 2005^100^ | Web-based stress management system | Self rated social support | +
Stress | 2 | Hasson, 2005^100^ | Web-based stress management system | Biological marker | +
Stress management | 1 | Zetterqvist, 2003^105^ | Interactive self help stress management program | Perceived Stress Scale
Stress management | 1 | Zetterqvist, 2003^105^ | Interactive self help stress management program | Hospital Anxiety and Depression Scale HADS | +
Stress management | 1 | Zetterqvist, 2003^105^ | Interactive self help stress management program | Anxiety | +
Stress management | 1 | Zetterqvist, 2003^105^ | Interactive self help stress management program | Depression | +
Stress management | 1 | Zetterqvist, 2003^105^ | Interactive self help stress management program | LE (Life Events) (Holmes and Rahes Scale) | 0
Stress management | 1 | Zetterqvist, 2003^105^ | Interactive self help stress management program | Perceived Social Support PS-family | 0
Stress management | 1 | Zetterqvist, 2003^105^ | Interactive self help stress management program | Perceived Social Support PS-friends | 0

ASQ=Attributional style questionnaire; BAI=Beck anxiety inventory; BDI= Beck depression inventory; CBT=cognitive behavioral therapy; CoNeg=composite index for negative situations; CoPos=composite index for positive situations; CES–D = Center for Epidemiologic Studies Depression Scale; EQ5D = EuroQoL; HADS = Hospital Anxiety and Depression Scale; QoL = quality of life; PS+ perceived social support system

Table 14

Grade of the body of evidence addressing CHI impact on intermediate outcomes in mental health.

1 | Protection against risk of bias (relates to study design, study quality, reporting bias) | Moderate
2 | Number of studies | 8
3 | Did the studies have important inconsistency? y (−1); n (0) | 0
4 | Was there some (−1) or major (−2) uncertainty about the directness or extent to which the people, interventions and outcomes are similar to those of interest? Some (−1); major (−2); none (0) | −1
5 | Were the studies sparse or imprecise? y (−1); n (0) | −1
6 | Did the studies show strong evidence of association between intervention and outcome? “strong^*^” (+1); “very strong^†^” (+2); No (0) | 0
| Overall grade of evidence ‡ | Low

* if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders

† if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity

‡ (high, moderate, low):if above score is (+), increase grade; if above score is (−), decrease grade from high to moderate (−1) or low (−2).

#### Strengths and Limitations of the Evidence

The volume of the literature in this area was small. Four studies evaluated several domains of CHI impact on intermediate outcomes related to depression or anxiety, 98,99 two studies evaluated the impact on stress,100 one evaluated the impact on stress management, and 101one study evaluated the impact on social phobia102 (Appendix G, Evidence Tables 23–25). The quality of these eight trials was variable, ranging from moderate to very low study quality scores,4 with several studies lacking in one or more methodological domains of RCT quality as measured by the Jadad criteria (Appendix G, Evidence Table 1). Postintervention evaluations ranged from as little as 1 month to as many as 6 months. The overall strength of the body of this evidence (Table 14) was graded as low, based on a modified version of the GRADE criteria5 and Chapter 11 of the EPC Manual.6

#### General Study Characteristics

These studies involved predominately married or cohabitating female adults of varying race and ethnicities. They ranged from 13 to 75 years of age with widely varying educational backgrounds. Outcomes of interest included impact on depressive symptoms,98 99 103,104 impact on anxiety levels, 98,103,104 change in the degree to which problems affect one’s ability to conduct normal activities,98 impact on dysfunctional thoughts,99 improvements in knowledge of therapy including cognitive-behavioral theory (CBT),99 changes in perceived stress scores,101 self-rated self-management,100,105 self-rated sleep quality,100 self-rated mental energy,100 self-rated concentration,100 self-rated social support,100 quality of life, 104 and change in measured biologic marker levels.100 Samples sizes were relatively small, ranging from 78^101^ to 182^100^ subjects per arm of the study (Appendix G, Evidence Tables 23 and 24).

#### Outcomes

##### Depression/anxiety

Proudfoot et al98 evaluated the impact of Web-based cognitive-behavioral therapy (CBT) on patients with diagnoses of depression, anxiety, and/or mixed depression with anxiety. Use of the “Beating the Blues” online CBT intervention was associated with improvements on the Beck depression inventory (BDI) (p=0.0006),98 Beck anxiety inventory (BAI) (p=0.06),98 Work and Social Adjustment Scale (p=0.002),98 and Attributional Style questionnaire (p<0.001 for negative situations and p<0.008 for positive situations).98

Christensen et al99 also evaluated the impact of a Web-based CBT application among patients who scored above 22 on the Kessler psychological distress scale and who were not currently receiving any treatment. The MoodGYM CBT intervention was associated with improvements in depressive symptoms on the CES-D scores (p=0.05) and dysfunctional thoughts via the Automatic Thoughts Questionnaire (p=0.05) compared to controls (Appendix G, Evidence Table 25).

Neil et al106 evaluated the impact of adherence to interactive consumer Web site-based therapy among depressed and/or anxious youth. The first adolescent sample consisted of 1000 school students who completed the MoodGYM program in a classroom setting over five weeks as part of n RCT. The second sample consisted of 7207 adolescents who accessed the MoodGYM program spontaneously and directly through the open Web-based access. The results of this evaluation indicate that adolescents in the school-based sample completed significantly more online exercises (mean = 9.38, SD = 6.84) than adolescents in the open-access community sample (mean = 3.10, SD = 3.85; t1088.62= −28.39, p<0.001).

Warmerdam et al 107 evaluated the effectiveness of Internet-based Cognative Behaviroal Therapy (CBT) vs. Internet-based Problem Solving Therapy (PST) on Depressive symptoms among community dwelling adults. Outcomes were evaluated at 5, 8 and 12 weeks post intervention. The results indicate significant improvements in between-group effect sizes for depressive symptoms, 0.54 for CBT after 8 weeks (95 percent confidence interval (CI): 0.25 – 0.84) and 0.47 for PST after 5 weeks (95 percent CI: 0.17 – 0.77) as compared to wait list controls. These effects were further improved at 12 weeks in both treatment groups (CBT: 0.69, 95 percent CI: 0.41 – 0.98; PST: 0.65, 95 percent CI: 0.36 – 0.95).

##### Phobia

FearFighter is an online CHI application designed to reduce symptoms of phobia/panic disorders (agoraphobia, social phobia, and specific phobias). 108 In this study FearFighter was compared to guided Internet-based self-help relaxation therapy (Managing Anxiety group [MA]). Both arms also received periodic phone or email followup from a therapist. At 1 month, patients in the FearFighter group scored better than those in the MA group on several phobia subscales as assessed by self-report and blinded raters using the main problems and goals subscale (p<0.001), FQ global phobias subscale (p<0.001), and FQ global impression score (p<0.001) (Appendix G, Evidence Table 25).

##### Stress

MyStudentBody is a Web-based CHI application, which is designed to reduce symptoms of stress among college students. Chiauzzi et al101 evaluated the effects of this application as compared to use of a control Web site and a non-Internet Web site control group. No significance between group differences in perceived stress was detected at 6-month followup.

Hasson et al100 conducted an evaluation of a Web-based health promotion tool on mental and physical well-being and stress-related biological markers. At 6-month postintervention followup, the intervention group had improved significantly compared to the reference group on ratings of ability to manage stress (p=0.001), sleep quality (p=0.04), mental energy (p=0.002), concentration ability (p=0.038), and social support (p=0.049). The anabolic hormone dehydroepiandosterone sulphate (DHEA-S) decreased significantly in the reference group as compared to unchanged levels in the intervention group (p=0.04). Neuropeptide Y (NPY) increased significantly (p=0.002), and Chromogranin A (CgA) decreased significantly in the intervention group (p=0.001) as compared to the reference group, while tumor necrosis factor α (TNFα) decreased significantly in the reference group compared to the intervention group (p<0.016). These results were consistent with a beneficial effect of this CHI application on several indicators of well-being and stress-related biomarkers (Appendix G, Evidence Table 25).

Zetterqvist et al 105 evaluated the effects of an internet-based self-help stress management program. The program was entirely delivered via the internet and included applied relaxation, problem solving, time management, and cognitive restructuring. The results of this investigation indicate that no measureable intervention effect was found in that both the treatment and control groups improved significantly at follow up in terms of perceived stress scores and the Hospital Anxiety and Depression Scale. In addition, participant attrition was significant.

### Asthma and Chronic Obstructive Pulmonary Disease

#### Summary of the Findings

Three studies evaluated the impact of CHI applications on intermediate outcomes in asthma8,10,109 and one in chronic obstructive pulmonary disease (COPD).110 Outcomes of interest included adherence, change in behavior in relation to rescue inhaler availability, asthma knowledge, change in asthma knowledge, dyspnea knowledge, and self-efficacy in managing dyspnea (Table 15). Across these studies, the body of the scientific evidence suggested that most CHI applications intended for use by individuals with asthma or COPD had variable results. Significant changes were noticed in the areas of change in knowledge.

Table 15

Results of studies on CHI applications impacting intermediate outcomes in asthma and COPD (N=4).

Target condition | N | Author, year | Interventions | Primary outcomes measured | Effect of CHI Applications^*^
Asthma | 3 | Jan et al 7007^10^ | Asthma education and an interactive asthma monitoring system | Monitoring adherence (peak flow meter technique score) | 0
Asthma | 3 | Jan et al 7007^10^ | Asthma education and an interactive asthma monitoring system | Monitoring adherence (asthma diary entries per month) | +
Asthma | 3 | Jan et al 7007^10^ | Asthma education and an interactive asthma monitoring system | Therapeutic adherence (DPI or MDI plus spacer technique score | 0
Asthma | 3 | Jan et al 7007^10^ | Asthma education and an interactive asthma monitoring system | Therapeutic adherence | 0
Asthma | 3 | Jan et al 7007^10^ | Asthma education and an interactive asthma monitoring system | Therapeutic adherence (adherence to inhaled corticosteroid) | 0
Asthma | 3 | Joseph, et al 2007^109^ | “Puff City” Internet intervention | Controller medication adherence: | 0
Asthma | 3 | Joseph, et al 2007^109^ | “Puff City” Internet intervention | Positive, no negative, or negative behavior change | 0
Asthma | 3 | Joseph, et al 2007^109^ | “Puff City” Internet intervention | Rescue inhaler availability: positive behavior, no negative, or negative behavior change | 0
Asthma | 3 | Krishna et al 2003^8^ | Internet-enabled asthma education program | Asthma knowledge score (caregivers of children 0–6 17 years old) | +
Asthma | 3 | Krishna et al 2003^8^ | Internet-enabled asthma education program | Asthma knowledge score (caregivers of children 7–17 17 years old) | +
Asthma | 3 | Krishna et al 2003^8^ | Internet-enabled asthma education program | Asthma knowledge score (children 7–17 17 years old) † | +
Asthma | 3 | Krishna et al 2003^8^ | Internet-enabled asthma education program | Change in knowledge (caregivers of children 0–6 17 years old) † | +
Asthma | 3 | Krishna et al 2003^8^ | Internet-enabled asthma education program | Change in knowledge (caregivers of children 7–17 years old) | +
Asthma | 3 | Krishna et al 2003^8^ | Internet-enabled asthma education program | Change in knowledge (children 7–17 17 years old) | +
COPD | 1 | Nguyen et al 2008^9^ | Internet-based dyspnea self-management | Dyspnea knowledge score (range 0–15 17 years old) | +
COPD | 1 | Nguyen et al 2008^9^ | Internet-based dyspnea self-management | Self-efficacy score for managing dyspnea (range 0–10 17 years old) | 0

* (+) positive impact of the CHI application on outcome; (−) negative impact of the CHI application on outcome; (0) no impact or not a significant of the CHI application on outcome

† while the CHI application showed positive impact in knowledge scores across groups, the change in scores was most significant in these two groups using the application DPI=dry powder inhaler; MDI=metered dose inhaler

#### Strengths and Limitations of the Evidence

Overall the volume of the literature in this area is small. There were only three studies on asthma and one on COPD. They evaluated several domains of CHI impact on intermediate outcomes. Studies addressing intermediate outcomes in asthma had a wide range of study participants, ranging from very low (<30 participants per arm)8 to low (>70 participants per arm).10,109 The one study addressing intermediate outcomes of CHI applications on COPD had a small sample size (<30 participants per arm)110(Appendix G, Evidence Tables 26–28). The quality of these four trials was moderate to low. All studies lacked information on blinding, were single blinded, and/or used inappropriate blinding methods as measured by the Jadad criteria4 (Appendix G, Evidence Table 1). Consumer postintervention evaluations ranged from as little as 12 weeks to as many as 6 months. The overall strength of the body of this evidence (Table 16) was graded as low based on a modified version of the GRADE criteria5 and Chapter 11 of the EPC Manual.6

Table 16

Grade of the body of evidence addressing CHI impact on intermediate outcomes in asthma/COPD.

1 | Protection against risk of bias (relates to study design, study quality, reporting bias) | Moderate
2 | Number of studies | 4
3 | Did the studies have important inconsistency? y (−1); n (0) | 0
4 | Was there some (−1) or major (−2) uncertainty about the directness or extent to which the people, interventions and outcomes are similar to those of interest? Some (−1); major (−2); none (0) | 0
5 | Were the studies sparse or imprecise? y (−1); n (0) | −1
6 | Did the studies show strong evidence of association between intervention and outcome? “strong^*^” (+1); “very strong^†^” (+2); No (0) | 0
| Overall grade of evidence ‡ | Low

* if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders

† if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity

‡ (high, moderate, low):if above score is (+), increase grade; if above score is (−), decrease grade from high to moderate (−1) or low (−2).

#### General Study Characteristics

Studies that evaluated the impact of CHI applications on asthma-related intermediate outcomes looked at individuals under the age of 17 years, and/or their caregivers. The population of interest in the study addressing COPD was much older–greater than 68 years old. Information regarding gender across these studies was reported and can be found in Appendix G, Evidence Table 26. Information on race/ethnicity was reported in only one study8 where the population was identified as mainly white, non-Hispanic. The education level of participants (children) in studies addressing asthma was not reported. In one study where caregivers were under evaluation,10 over 50 percent of the caregivers had a high school diploma or below. The education level of caregivers in the other study8 was not reported; education levels of the children were reported, but were not of value for this report (Appendix G, Evidence Tables 26 and 27).

#### Outcomes

##### Adherence

The impact of CHI applications on adherence was measured in two of the three articles addressing asthma. Jan et al10 evaluated Blue Angel for Asthma Kids, an Internet-based interactive asthma educational and monitoring program. The intervention group was taught to monitor their peak expiratory flows (PEF) and asthma symptoms daily on the Internet. The also received an interactive response consisting of a self-management plan from the Blue Angel monitoring program. The control group received a traditional asthma care plan consisting of a written asthma diary supplemented with instructions for self-management. The results of this study indicate that the intervention group experienced significantly decreased nighttime (p=0.028) and daytime symptoms (p= 0.009); improved morning (p=0.017) and night peak expiratory flow (p=0.010); increased adherence rates (p<0.05); improved well-controlled asthma rates (p<0.05); improved knowledge regarding self-management (p<0.05); and improved quality of life (p<0.05) when compared with conventional management.

Joseph et al109 evaluated a multimedia, Web-based asthma management program to specifically target urban high school students. The program uses “tailoring,” in conjunction with theory based models, to alter behavior through individualized health messages based on the user’s beliefs, attitudes, and personal barriers to change. The control group was given access to a generic asthma Website. The results of this investigation indicate that at 12 month follow up, the intervention group reported fewer symptom-days (p= 0.003), fewer symptom-nights (p=0.009), fewer school days missed (p=0.006), fewer restricted activity days (p=0.02) and fewer hospitalizations for asthma (p=0.01) when compared with control (Appendix G, Evidence Table 28).

##### Knowledge

Krishna et al8 evaluated whether health outcomes of children who have asthma can be improved through the use of an Internet-enabled interactive multimedia asthma education program. Children and caregivers in both the intervention and control groups received traditional patient education. Intervention group participants also received self-management education through the Interactive Multimedia Program for Asthma Control and Tracking. Results indicate that the intervention significantly increased asthma knowledge of children (p<0.001) as compared to controls.

Nguyen et al 111 measured the efficacy of an Internet-based and face-to-face self management program in people living with COPD. The content of the two programs was similar, focusing on education, skills training, and ongoing support for dyspnea self-management. The only difference was the mode of administration (Internet/personal digital assistant (PDA) or face-to-face) of the education sessions, reinforcement contacts, and peer interactions. The results indicate that there were improvements in knowledge of dyspnea management strategies in both groups, however there were no significant group by time differences. (Appendix G, Evidence Table 28).

##### Self efficacy

Nguyen et al 111 also measured the efficacy of an Internet-based and face-to-face self management program to increase self efficacy among people living with COPD. As outlined above, the content of the two programs were similar, focusing on education, skills training, and ongoing support for dyspnea self-management. The only difference was the mode of administration (Internet/personal digital assistant [PDA] or face-to-face) of the education sessions, reinforcement contacts, and peer interactions. The results indicate that there were improvements in self-efficacy for managing dyspnea in both groups, however there were no significant group by time differences (Appendix G, Evidence Table 28).

### Miscellaneous Intermediate Outcomes

#### Summary of the Findings

Sixteen studies evaluated the impact of CHI applications on intermediate outcomes across 13 other categorical diseases and health issues. These included cardiovascular disease,112,113 arthritis,114 back pain,115 behavioral risk factor management,116 cancer,15,117, caregiver decision-making,118 health behavior change,119 headache,120 HIV/AIDS,121 menopause/hormone replacement therapy (HRT),122,123 fall prevention,124 adolescent risk behavior, 125 and contraception9 (Appendix G, Evidence Tables 29–31). Across these studies, the CHI applications had varying effects on intermediate outcomes. The studies were too heterogeneous and the volume of studies on any single topic too few to support a conclusion about the effectiveness of CHI applications for these conditions.

#### Strengths and Limitations of the Evidence

The volume of the literature in this area is at a very early and incomplete stage of development. With the exception of studies focusing on cardiovascular disease, cancer, and menopause/HRT, which had two studies each, all other health issues had only one study evaluating an intermediate outcome for that topic area (Appendix G, Evidence Tables 29–31). The quality of these trials was variable with several studies lacking in one or more methodological domains of RCT quality as measured by the Jadad criteria4 (Appendix G, Evidence Table 1). The overall grade of this body of evidence was insufficient based on a modified version of the GRADE criteria5 and Chapter 11 of the EPC Manual.6

#### General Study Characteristics

Most of these studies involved adults of varying race and ethnicities, from 22 to 89 years of age, with widely varying educational backgrounds. One study125 involved adolescent teens aged 13–17. Outcomes of interest included self-efficacy,112,114,124 medication compliance,126 activity limitation,114 self-reported global health,114 arthritic pain,114 fat intake,116 physical activity,116 satisfaction with care,15 receipt of Pap smear,117 caregiver decisional confidence,118,121 decisionmaking skill,118,121 social isolation,118,121 preventive care uptake,119 headache symptoms,120 depressive symptoms,120 anxiety,120 reduced health status decline,121 knowledge,9,122,123 satisfaction with decisions,122 reduced decisional conflict,122 realistic health expectations,123 high cigarette use, frequent marijuana use, high alcohol use, problems at home, often feeling sad or upset, feeling sad or down lately, taking meds, having a love interest, having sex, desiring contraceptive information,125 and behavioral intention.127 Postintervention followup time ranged from immediate postintervention to 1 year. Samples sizes were generally small, ranging from 8 to 344 subjects per arm of the study, except for two larger studies which had sample sizes of 827 and 930 in each arm,116 and 940 and1066 in each arm119 (Appendix G, Evidence Tables 30 and 31).

#### Outcomes

##### Adolescent risk behavior

Paperny et al125 evaluated the effect of a written Personalized Health Risk Assesment (HRA) (controls) that is shared with a clinician to a computerized HRA that was (intervention #2) or was not (intervention number 1) shared with a clinician. Over 75 percent of the participants were White or of Asian descent, 52 percent were males, and approximately 10 percent were receiving financial assistance. The results indicated that significant postintervention reductions in high cigarette use (p=<0.01/p=<0.03); reductions in frequent marijuana use (p=<0.04/p=<0.03); reductions in problems with parents (p=0.001/p=0.001); and reductions in often sad, upset, or unhappy feelings (p=0.001/p=0.007) were achieved in both treatment groups (did not share computerized HRA with clinician/shared computerized HRA with clinician) as compared to controls (written HRA shared with clinicians). Significant reductions in high alcohol use (p=<0.02/NS), feeling sad or down lately (p=<0.04/NS), and has a current lover (p=<0.03/NS) were only significant in the group that did not share their HRA with the clinician. Finally there was no measureable effect of the intervention on having sexual intercourse (NS/NS) or taking medications (NS/NS).

##### Arthritis

Lorig et al114 conducted an evaluation of an Internet-based arthritis self-management program among patients with rheumatoid arthritis, osteoarthritis, or fibromyalgia. At 1-year postintervention, patients in the intervention group demonstrated significant improvement in health distress (p< 0.001), activity limitation (p< 0.001), self-reported global health (p=0.004), and pain (p<0.001) and self-efficacy (p=0.018). No impact was seen on health care utilization or health behaviors (Appendix G, Evidence Table 31).

##### Back pain

Buhrman et al115 investigated the impact of an Internet-based cognitive-behavioral intervention with telephone support for chronic back pain. At 3-month postintervention followup evaluation there was significant improvement for several Coping Strategies Subscale items including praying and hoping (p=0.032), catastrophizing (p=0.005), control of pain (p<0.001), and ability to decrease pain (p<0.0001). In addition, significant improvement was also found on Multidimensional Pain Inventory subscales for life control (p<0.001) and decrease of punishing responses (p<0.05). Results on the Pain Impairment Rating Scale showed a significant reduction (p<0.01), while a significant decrease was also found on the Hospital and Anxiety Depression Scale (p<0.001) (Appendix G, Evidence Table 31).

##### Behavioral risk factor control

Oenema et al116 evaluated the impact of an Internet-delivered, computer-tailored lifestyle intervention targeting saturated fat intake, physical activity (PA), and smoking cessation. At 1-month postintervention followup the intervention group had a significantly lower self-reported saturated fat intake (p<0.01) and a higher likelihood of meeting the physical activity guidelines among respondents who were insufficiently active at baseline (OR, 1.34, 95 percent CI, 1.001–1.80). No significant effects were found for self-reported smoking status (Appendix G, Evidence Table 31).

##### Contraception

Chewning 9 et al conducted a study to evaluate a computer-based contraceptive decision aid among young women. At 1-year postintervention followup, intervention participants demonstrated higher oral contraceptive knowledge than controls (p=0.00) (Appendix G, Evidence Table 31).

##### Cardiovascular disease

Kukafka et al112 investigated if a tailored, Web-based, cardiovascular disease educational system could influence self-efficacy regarding a patient’s likelihood of acting appropriately in response to acute myocardial infarction symptoms. At 3-months postintervention followup evaluation, patients in the Web-based intervention arm of the study demonstrated significant increases in self-efficacy to label symptom sensations (p<0.001), self-efficacy to respond to symptom sensations (p<0.05), and cognitive control self-efficacy (p<0.001) (Appendix G, Evidence Table 31).

##### Cancer

Jones et al15 conducted an investigation to compare the use and effect of a computer-based personalized information system for cancer patients using each patient’s medical record with a computer system providing only general information and with information provided in booklets. At postintervention followup, patients in the personalized computer intervention group were more likely to learn something new (p=0.03), thought that the information was relevant (p=0.02), and had higher satisfaction scores (p=0.04) than patients in the general computer information group. In addition, patients who used the printed booklets were more likely to feel overwhelmed by the information (p<0.001) and felt that the information was too limited (p<0.001). Finally, at 3-months postintervention, patients who used the printed booklets were less likely to prefer the computer to a 10-minute, in-person consultation (p<0.001). Campbell et al117 assessed the impact of computer-generated printed feedback on cervical screening among women who were under-screened for cervical cancer. Significant 6-month postintervention screening rates were demonstrated only among under-screened women between 50–70 years of age (p<0.5) (Appendix G, Evidence Table 31).

##### Caregiver decision

Brennan et al118 evaluated CompuLink, which is an online support application, designed to enhance decisionmaking confidence and skill by provision of information, decision-support tools, and communication (email). An evaluation of this application documented an association between CompuLink and significantly improved decisionmaking confidence (p<0.01). However no change was seen in terms of decisionmaking skill, social isolation, or health status (Appendix G, Evidence Table 31).

##### Fall prevention

Yardley et al124 conducted an evaluation of an interactive Web-based program that provides tailored advice about undertaking SBT activities among seniors 65–97 years of age. Postintervention evaluation suggests that there was a significant difference between the tailored and control groups on ratings of the personal relevance of the advice (p =0.014), self-efficacy for carrying out SBT (p=0.047), and intention to carry out strength and balance training (p=0.039). The intervention did not exert any measurable effects on reports of the advice being more suitable or interesting or expectation that the recommended activities would improve their balance (Appendix G, Evidence Table 31).

##### Health behavior change

Harari et al119 conducted an RCT to evaluate the impact on health behaviors and use of preventive health care services of a computer-generated, tailored, health education system. At 1-year followup evaluation there were no significant differences in self-reported health risk behavior, except for a small but statistically significant difference in adherence with recommended levels of physical activity (at least 5 times per week moderate to strenuous) (P = 0.03). In terms of preventive health care uptake, there was a significant increase in pneumococcal vaccination rates (P=0.04) among patients enrolled in the computer-based intervention (Appendix G, Evidence Table 31).

##### Headache

Devineni et al 120 evaluated an Internet-delivered behavioral intervention versus a symptom monitoring waiting list control group among patients with chronic headache. Two-month postintervention evaluations indicated significant reductions in headache index scores (p<0.05). There were also significant improvements on the Headache Symptom Questionnaire (p<0.01) and the Headache Disability Inventory (p<0.05) (Appendix G, Evidence Table 31).

##### HIV/AIDS

Brennan et al121 conducted a second study of CompuLink (see above) among persons living with HIV/AIDS. This investigation suggested an association between using CompuLink and reduced levels of social isolation (p<0.01) and improved decisionmaking confidence (p<0.0). However no change was seen in terms of decisionmaking skill or health status as compared to controls.

##### Menopause/HRT utilization

Shapira et al122 conducted an RCT of a computer-based hormone therapy (HT) decision-aid versus print material among postmenopausal women. At 3-months postintervention followup evaluation, there was no measurable difference between groups with respect to knowledge, satisfaction with decision, decisional conflict, or hormone therapy use. Rostom et al 123 conducted an investigation to compare the efficacy of a computerized decision aid compared to an audio booklet among women considering long-term HRT. The results of a postintervention evaluation indicated that the computerized decision aid intervention significantly increased realistic expectations (p=0.015) and knowledge (p=0.019) among women considering long term HRT (Appendix G, Evidence Table 31).

## Key Question 1c: What evidence exists that consumer health informatics applications impact relationship-centered outcomes?

### Summary of the Findings

Eight studies evaluated the impact of CHI applications on various aspects of relationship-centered outcomes (Tables 17 and 19, and Appendix G, Evidence Tables 32–34). Outcomes of interest include social support, quality of life, health information competence, decision confidence, improved decision making skill, reduced social isolation, level of positive interaction with the provider, and satisfaction with care. These outcomes were examined in the context of five health problems, which include breast cancer, caregiver decision making, osteoarthritis, newborn birth and delivery, and HIV/AIDS. Across these studies, the body of the scientific evidence indicated that most CHI applications evaluated to date had equivocal effects on relationship-centered health outcomes.

Table 17

Studies of CHI applications impacting relationship-centered outcomes in women with breast cancer (N=4).

Target condition | N | Author, year | Interventions | Primary outcomes measured
Caregiver decision making | 1 | Brennan, 1995^118^ | Experimental | Decision confidence
Caregiver decision making | 1 | Brennan, 1995^118^ | Experimental | Improved decision making skill
Caregiver decision making | 1 | Brennan, 1995^118^ | Experimental | Isolation
HIV/AIDS | 1 | Flatley-Brennan, 1998^121^ | Computer Link | Improved decision making confidence
HIV/AIDS | 1 | Flatley-Brennan, 1998^121^ | Computer Link | Improved decision making skill
HIV/AIDS | 1 | Flatley-Brennan, 1998^121^ | Computer Link | Reduced social isolation
HIV/AIDS | 1 | Flatley-Brennan, 1998^121^ | Computer Link | Differential decline in health status
Arthritis | 1 | Sciamanna, 2005^131^ | Patient satisfaction after intervention Satisfaction with care | Patient overall satisfaction score with the osteoarthritis care they are receiving
Arthritis | 1 | Sciamanna, 2005^131^ | Patient satisfaction after intervention Satisfaction with care | Peak consumption: max number of drinks per drinking day
Vaginal or c-section delivery | 1 | Montgomery, 2007^130^ | Information Decision analysis | DCS at followup
Vaginal or c-section delivery | 1 | Montgomery, 2007^130^ | Information Decision analysis | Difference between groups in total score on DCS (decision vs. usual care)
Vaginal or c-section delivery | 1 | Montgomery, 2007^130^ | Information Decision analysis | Odds ratio for caesarean (elective& emergency) vs. vaginal decision vs. usual care
Vaginal or c-section delivery | 1 | Montgomery, 2007^130^ | Information Decision analysis | Satisfaction with decision (decision analysis vs. usual care)
Vaginal or c-section delivery | 1 | Montgomery, 2007^130^ | Information Decision analysis | Mode of delivery - elective caesarean
Vaginal or c-section delivery | 1 | Montgomery, 2007^130^ | Information Decision analysis | Delivery - emergency caesarean
Vaginal or c-section delivery | 1 | Montgomery, 2007^130^ | Information Decision analysis | Delivery - vaginal birth

CHESS = Comprehensive Health Enhancement Support System; DCS= decisional conflict scale; IVD= interactive video disc system

Table 19

Results of studies on CHI applications impacting relationship-centered outcomes in breast cancer (N=4).

Target condition | N | Author, year | Interventions | Primary outcomes measured | Effect of CHI Applications
Breast cancer | 4 | Green, 2005^128^ | Counseling and Computer | Alter content of discussions | +
Breast cancer | 4 | Green, 2005^128^ | Counseling and Computer | Change the way they used their time | +
Breast cancer | 4 | Green, 2005^128^ | Counseling and Computer | Used time more efficiently | +
Breast cancer | 4 | Green, 2005^128^ | Counseling and Computer | Skip material typically present | +
Breast cancer | 4 | Green, 2005^128^ | Counseling and Computer | Effectiveness of counseling session | +
Breast cancer | 4 | Green, 2005^128^ | Counseling and Computer | Shorter counseling sessions | +
Breast cancer | 4 | Gustafson, 2008^14^ | Internet CHESS | Social support | +
Breast cancer | 4 | Gustafson, 2008^14^ | Internet CHESS | Quality of life | +
Breast cancer | 4 | Gustafson, 2008^14^ | Internet CHESS | Health competence | +
Breast cancer | 4 | Gustafson, 2001^13^ | CHESS | Information competence | +
Breast cancer | 4 | Gustafson, 2001^13^ | CHESS | Participation | +
Breast cancer | 4 | Gustafson, 2001^13^ | CHESS | Confidence in doctors | +
Breast cancer | 4 | Maslin, 1998^129^ | IVD shared decision making | Anxiety and depression | +
Breast cancer | 4 | Maslin, 1998^129^ | IVD shared decision making | Satisfaction with treatment decision | 0

* (+) positive impact of the CHI application on outcome; (−) negative impact of the CHI application on outcome; (0) no impact or not a significant of the CHI application on outcome CHESS = Comprehensive Health Enhancement Support System; IVD = interactive videodisc system

### Strengths and Limitations of the Evidence

Eight studies evaluated several domains of CHI impact on relationship-centered care outcomes. With the exception of breast cancer, for which there were four studies regarding relationship-centered outcomes,13,14,128,129 all other topics were evaluated by a single study: HIV/AIDS,121 newborn delivery,130 osteoarthritis,131 and Alzheimer’s disease and caregiver decisionmaking.118 Only one study130 was large, with 147 to 201 subjects per arm of the study; all other studies relied on very small sample sizes (< 80 subjects per arm) (Appendix G, Evidence Tables 32–34). The quality of these eight trials was variable with several studies lacking in one or more methodological domains of RCT quality as measured by the Jadad4 criteria (Appendix G, Evidence Table 32–34). Patient postintervention evaluations ranged from as little as 2 months to as many as 12 months. The overall strength of the body of this evidence (Table 18) was graded as moderate for studies on breast cancer based on a modified version of the GRADE criteria5 and Chapter 11 of the EPC Manual.6

Table 18

Grade of the body of evidence addressing CHI impact on relationship-centered outcomes in breast cancer.

1 | Protection against risk of bias (relates to study design, study quality, reporting bias | Moderate
2 | Number of studies | 4
3 | Did the studies have important inconsistency? y (−1); n (0) | 0
4 | Was there some (−1) or major (−2) uncertainty about the directness or extent to which the people, interventions and outcomes are similar to those of interest? Some (−1); major (−2); none (0) | 0
5 | Were the studies sparse or imprecise? y (−1); n (0) | −1
6 | Did the studies show strong evidence of association between intervention and outcome? “strong^*^” (+1); “very strong^†^” (+2); No (0) | 0
| Overall grade of evidence ‡ | Low

* if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders

† if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity

‡ (high, moderate, low): if above score is (+), increase grade; if above score is (−), decrease grade from high to moderate (−1) or low (−2).

### General Study Characteristics

The studies that were evaluations of the impact of CHI applications on relationship-centered care generally were tested among an adult, non-elderly population. The mean age of study participants across studies was 32 to 52 years. One additional study was among participants with an average age of 64. Information regarding gender across these studies was generally not reported. Because 4 of the studies were conducted in the context of breast cancer13,14,128,129 and a fifth study was conducted in the context of newborn birth decision,130 it can be inferred that these six studies were completely among female participants. Only six studies reported on the race/ethnicity of study participants. Of these, 4 studies included only non-Hispanic white participants. One additional study included whites and African Americans while a final study included whites, African-Americans, Asian/Pacific Islanders and Hispanics (Appendix G, Evidence Tables 32 and 33).

### Outcomes

#### Breast cancer

When evaluating social support, quality of life, and health confidence among women with breast cancer, Gustafson et al14 found that the Comprehensive Health Enhancement Support System (CHESS) provided significantly more social support (p=0.003) and enabled greater quality of life (p=0.029) and health information competence (p=0.007) than Internet access alone at 2 months. The effect of CHESS remained for social support (p=0.027) and quality of life (p=0.047) at 4 months, while no effects of CHESS were observed at 9 months for social support, quality of life, or health information confidence.

Gustafson13 also evaluated the effectiveness of the CHESS among younger underserved women. At the 2-month postintervention followup, CHESS had significant impact on patient information competence (p<0.05), level of comfort with the health care system (p<0.01), and increased confidence in doctors (p<0.05).

Maslin et al129 studied the effectiveness of a shared decision making computer program (interactive video disc) for women with early breast cancer contemplating surgical and chemotherapeutic options. Use of the interactive video disk did not have significant effect on the treatment decisions made by women participating in the study.

Green et al128 compared the effectiveness of counseling alone versus counseling preceded by use of a computer-based decision aid among women referred to genetic counseling for a family or personal history of breast cancer. Postintervention evaluations suggested that participants rated 11 of 12 specific attributes of the effectiveness of the counseling sessions significantly higher (P < 0.0001) compared with the counselors. Overall, computer program use resulted in shorter face-to-face counseling sessions among women at low risk for carrying breast cancer gene mutations (p=0.027) (Table 19, and Appendix G, Evidence Table 34).

#### Caregiver decisionmaking (Alzheimer’s disease)

CompuLink118is an online support application designed to enhance decisionmaking confidence and skill by provision of information, decision support tools, and communication (email). An evaluation of this application documented an association between use of CompuLink and significantly improved decisionmaking confidence (p<0.01). No change was seen in terms of decisionmaking skill, social isolation, or health status (Appendix G, Evidence table 34).

#### HIV/AIDS

In another study of CompuLink 121 among persons living with HIV/AIDS, data suggested an association between use of CompuLink and reduced levels of social isolation (p<0.01) and improved decisionmaking confidence (p<0.0). No change was seen in terms of decisionmaking skill or health status as compared to controls (Appendix G, Evidence table 34).

#### Osteoarthritis

Sciamanna et al131 evaluated the effect of a Web-based osteoarthritis educational application on patients’ perceptions of the quality of their osteoarthritis care. This application failed to produce a measurable effect on patient satisfaction with osteoarthritis care as compared to controls (Appendix G, Evidence table 34).

#### Newborn delivery

Montgomery et al130 investigated the effects of two computer-based decision aids (an information program and individualized decision analysis) on decisional conflict and actual mode of delivery among a group of pregnant women with one previous caesarean section. The results of this study indicate that there was no significant effect of either of these computer-based decision aids on decisional conflict or mode of delivery (Appendix G, Evidence table 34).

## Key Question 1d: What evidence exists that consumer health informatics applications impact clinical outcomes?

### Breast Cancer

#### Summary of the Findings

Three studies addressed the impact of CHI applications on breast cancer clinical outcomes. Outcomes of interest include quality of life, well-being, physical functioning, and anxiety (Table 20). All three studies were RCTs and the quality of these studies varied from very low to low. Across these studies the body of the scientific evidence suggests that CHI applications intended for use by individuals with breast cancer have a neutral to positive impact.

Table 20

Results of studies on CHI applications impacting clinical outcomes in breast cancer (N=3)

Target condition | N | Author, year | Interventions | Primary outcomes measured | Effect of CHI Application^*^
Breast Cancer | 3 | Gustafson, 2001^13^ | CHESS | Social/family well being (quality of life) | 0
Breast Cancer | 3 | Gustafson, 2001^13^ | CHESS | Emotional well-being (quality of life) | 0
Breast Cancer | 3 | Gustafson, 2001^13^ | CHESS | Functional well-being (quality of life) | 0
Breast Cancer | 3 | Gustafson, 2001^13^ | CHESS | Breast cancer concerns (quality of life) | 0
Breast Cancer | 3 | Gustafson, 2008^14^ | CHESS | Quality of life | 0
Breast Cancer | 3 | Maslin, 1998^129^ | IVD shared decision programme | Anxiety and depression^†^ | +
Breast Cancer | 3 | Maslin, 1998^129^ | IVD shared decision programme | Physical functioning | +

* (+) positive impact of the CHI application on outcome; (−) negative impact of the CHI application on outcome; (0) no impact or not a significant of the CHI application on outcome

† significant impact of CHI was seen in this outcome CHESS= Comprehensive Health Enhancement Support System; IVD= interactive video disc system

#### Strengths and Limitations of the Evidence

Overall the volume of the literature in this area is small (three studies). Many domains of CHI application impact on clinical outcomes with individuals with breast cancer were measured. The three studies had low13 to very low14,129 numbers of study participants. Followup periods were either shot (2 months) or not reported (Appendix G, Evidence Tables 35–37). None of the studies contained any information on blinding as measured by the Jadad criteria4 (Appendix G, Evidence Table 1). The overall strength of the body of this evidence (Table 21) was graded as low based on a modified version of the GRADE criteria5 and Chapter 11 of the EPC Manual6

Table 21

Grade of the body of evidence addressing CHI impact on clinical outcomes in individuals with breast cancer.

1 | Protection against risk of bias | Low
2 | Number of studies | 3
3 | Did the studies have important inconsistency? y (−1); n (0) | 0
4 | Was there some (−1) or major (−2) uncertainty about the directness or extent to which the people, interventions and outcomes are similar to those of interest? Some (−1); major (−2); none (0) | 0
5 | Were the studies sparse or imprecise? y (−1); n (0) | −1
6 | Did the studies show strong evidence of association between intervention and outcome? “strong^*^” (+1); “very strong^†^” (+2); No (0) | 0
| Overall grade of evidence ‡ | Very low

* if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders

† if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity

‡ (high, moderate, low):if above score is (+), increase grade; if above score is (−), decrease grade from high to moderate (−1) or low (−2).

#### General Study Characteristics

Studies that evaluated the impact of CHI applications on breast cancer clinical outcomes- outcomes looked at individuals between the ages of 44 and 52; age was only reported in two studies.14,129 Information regarding gender across these studies was not reported. Information on race/ethnicity was reported in only in two studies as predominantly white, non-Hispanic. 14,129 (Appendix G, Evidence Tables 36 and 37).

#### Outcomes

To assess the impact of a computer-based patient support system on quality of life in younger women with breast cancer, 246 newly diagnosed breast cancer patients under age 60 were randomized to a control group or an experimental group that received Comprehensive Health Enhancement Support System (CHESS), a home-based computer system providing information, decision-making, and emotional support. At 5-month followup, no statistical difference was shown in quality of life between the control and CHESS group.13 No significant improvement in quality of life was demonstrated by the same authors in another study in 257 breast cancer patients after 9-month followup.14

Another study evaluated the usefulness of a shared decisionmaking program for women with early breast cancer; looking at surgical and adjuvant treatment options (chemotherapy) using a personalized computerized interactive video system.129 One hundred patients were randomized to an intervention group (n=51) or control group (n=49). The study showed improvement in the following clinical outcomes: a significant fall in anxiety after 9 months measured by the Hospital Anxiety and Depression Scale (p<0.001), improvement in the physical functioning sub-score of general quality of life measured by the Medical Outcomes Study Short Form 36 questionnaire (Table 22, and Appendix G, Evidence Table 37).

Table 22

Results of studies on CHI applications impacting clinical outcomes in diabetes mellitus (N=3).

Target condition | N | Author, year | Interventions | Primary outcomes measured | Effect of CHI Application^*^
Diabetes | 3 | Homko, 2007^92^ | Telemedicine | Insulin therapy | 0
Diabetes | 3 | Homko, 2007^92^ | Telemedicine | FBS | 0
Diabetes | 3 | Homko, 2007^92^ | Telemedicine | A1c at time of delivery | 0
Diabetes | 3 | Tjam, 2006^132^ | Individuals with interactive Internet program | A1C (%) | 0
Diabetes | 3 | Tjam, 2006^132^ | Individuals with interactive Internet program | FBG (MMOL/L) | 0
Diabetes | 3 | Tjam, 2006^132^ | Individuals with interactive Internet program | TC (MMOL/L | 0
Diabetes | 3 | Tjam, 2006^132^ | Individuals with interactive Internet program | TG (MMOL/L) | 0
Diabetes | 3 | Wise et al 94 | Interactive computer assessment | HbA1c | +

* (+) positive impact of the CHI application on outcome; (−) negative impact of the CHI application on outcome; (0) no impact or not a significant of the CHI application on outcome

† significant impact of CHI was seen in this outcome

FBG = fasting blood glucose; FBS = fasting blood sugar; HbA1c = hemoglobin A1c; MMOL/L = millimoles per litre; TC = total cholesterol; TG = triglycerides

### Diabetes Mellitus

#### Summary of the Findings

Three studies addressed the impact of CHI applications on clinical outcomes in individuals with diabetes mellitus. Outcomes of interest were the use of insulin therapy, and measures of hemoglobin A1c (HbA1c), total glucose, triglycerides, and fasting blood glucose. (Table 22) All three studies were RCTs and the quality of these studies was low (Appendix G, Evidence Table 1). There was no indication of significant impact of the CHI application on outcomes in two studies.92,132 One study94 showed a positive impact on HbA1c.

#### Strengths and Limitations of the Evidence

The volume of this literature is small. All three studies had a small number (<30) participants. Followup periods ranged from 37 weeks92 to 12 months132 (Appendix G, Evidence Tables 35–37). Blinding, as measured by the Jadad criteria,4 was not reported in any of the studies (Appendix G, Evidence Table 1). The overall strength of the body of this evidence (Table 23-A) was graded as low based on a modified version of the GRADE criteria5 and Chapter 11 of the EPC Manual6

Table 23-A

Grade of the body of evidence addressing CHI impact on clinical outcomes in individuals with diabetes mellitus.

1 | Protection against risk of bias | Low
2 | Number of studies | 3
3 | Did the studies have important inconsistency? y (−1); n (0) | 0
4 | Was there some (−1) or major (−2) uncertainty about the directness or extent to which the people, interventions and outcomes are similar to those of interest? Some (−1); major (−2); none (0) | 0
5 | Were the studies sparse or imprecise? y (−1); n (0) | −1
6 | Did the studies show strong evidence of association between intervention and outcome? “strong^*^” (+1); “very strong^†^” (+2); No (0) | 0
| Overall grade of evidence ‡ | low

* if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders

† if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity

‡ (high, moderate, low): if above score is (+), increase grade; if above score is (−), decrease grade from high to moderate (−1) or low (−2).

#### Outcomes

To demonstrate the feasibility of monitoring glucose control among indigent women with GDM over the Internet, women with GDM were randomized to either the Internet group (n=32) or the control group (n=25).92 Patients in the Internet group were provided with computers and/or Internet access if needed. A Web site was established for documentation of glucose values and communication between the patient and the health care team. Women in the control group maintained paper log books, which were reviewed at each prenatal visit. There was no difference between the two groups in regards to either fasting or postprandial blood glucose values, although more women in the Internet group received insulin therapy (31 percent vs. 4 percent; P<0.05). There were also no significant differences in pregnancy and neonatal outcomes between the two groups. 92

Another study compared physiological outcomes between an interactive diabetes Internet program and the Diabetes Education Centers with respect to followup care for on-going diabetes management. Participants were followed for 1 year and were assessed at baseline, 3 months, 6 months, and 1 year. Triglyceride levels improved significantly in the intervention group from baseline to followup. Hemoglobin A1c levels were also significantly improved in the intervention group at 3 months, but this improvement was not sustained to the 6-month or 1-year time points.

Wise et al94 evaluated the impact of an interactive computer program on process and clinical outcomes among insulin-dependent and noninsulin-dependent patients with diabetes. At 4–6 months, this application significantly improved HBA1c among both insulin dependent and non-insulin dependent (Appendix G, Evidence Table 37).

### Diet, Exercise, Physical Activity, not Obesity

#### Summary of the Findings

Five studies addressed the impact of CHI applications on clinical outcomes related to diet, exercise, or physical activity, not obesity. Clinical outcomes of interest were weight loss, change in body weight, and change in body fat (Table 23-B). All of the studies were RCTs and four of the five had low study quality (Appendix G, Evidence Table 1). One study by Tate et al44 received a Jadad score of high due to the fact that it was blinded. Overall the studies showed results indicating either no impact or a positive impact on one of the outcomes.

Table 23-B

Results of studies on CHI applications impacting clinical outcomes in diet, exercise, physical activity, not obesity (N=5).

Target condition | N | Author, year | Interventions | Primary outcomes measured | Effect of CHI Application^*^
Diet/exercise/physical activity | 5 | Adachi, 2007^†,17^ | Computer tailored program with 6-mos weight and targeted behavior’s self- monitoring, (Group KM) Computer tailored program only, (Group K) | Percent weight loss | +
Diet/exercise/physical activity | 5 | Hunter, 2008^85^ | BIT | Body weight (kg) | +
Diet/exercise/physical activity | 5 | McConnon, 2007^81^ | Internet group | Loss of 5% or more body weight (12 months) | 0
Diet/exercise/physical activity | 5 | Tate, 2006^44^ | Tailored Computer- Automated Feedback Human Email Counseling | Weight loss | +
Diet/exercise/physical activity | 5 | Williamson, 2006^83^ | Interactive Nutrition education program and Internet counseling behavioral therapy for the intervention group | Body weight ‡(kg) | 0
Diet/exercise/physical activity | 5 | Williamson, 2006^83^ | Interactive Nutrition education program and Internet counseling behavioral therapy for the intervention group | Body fat \|\|(%) | +

* (+) positive impact of the CHI application on outcome; (−) negative impact of the CHI application on outcome; (0) no impact or not a significant of the CHI application on outcome

† the greatest effect of the intervention was seen at the 1-month post intervention time interval

‡ both parents and children showed a decrease in bodyweight at 6months, at the end of the followup period of 2 years all weight lost was regained and there was no difference between intervention and control.

|| positive impact of reduction of body fat was greater in children and was only reported for the first 6 months post-intervention BIT= behavioral Internet treatment; BMI= body mass index: ; kg = kilogram

#### Strengths and Limitations of the Evidence

The volume of this literature is small, including only five studies addressing clinical outcomes in CHI applications focused on in diet, exercise, physical activity, not obesity. Four of the studies has small sample sizes of under 80 participants17,81,83,85 On study had a large number of study participants; over 200.^44^ Followup periods ranged from 6 to 24 months. Blinding, as measured by the Jadad criteria,4 was reported in one44 study but not in the remaining 4 of the other studies (Appendix G, Evidence Table 1). The overall strength of the body of this evidence (Table 24) was graded as low based on a modified version of the GRADE criteria5 and Chapter 11 of the EPC Manual.6

Table 24

Grade of the body of evidence addressing CHI impact on clinical outcomes related to diet, exercise, or physical activity, not obesity.

1 | Protection against risk of bias | Low
2 | Number of studies | 5
3 | Did the studies have important inconsistency? y (−1); n (0) | 0
4 | Was there some (−1) or major (−2) uncertainty about the directness or extent to which the people, interventions and outcomes are similar to those of interest? Some (−1); major (−2); none (0) | 0
5 | Were the studies sparse or imprecise? y (−1); n (0) | −1
6 | Did the studies show strong evidence of association between intervention and outcome? “strong^*^” (+1); “very strong^†^” (+2); No (0) | 1
| Overall grade of evidence ‡ | Low

* if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders

† if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity

‡ (high, moderate, low):if above score is (+), increase grade; if above score is (−), decrease grade from high to moderate (−1) or low (−2).

#### Outcomes

To assess computer-tailored feedback, 192 adults with a mean age of 49.2 years (SD 9.8) and a mean BMI of 32.7 (SD 3.5) were randomized to one of three Internet treatment groups: no counseling, computer-automated feedback, or human email counseling. All participants received one weight loss group session, coupons for meal replacements, and access to an interactive Web site. The human email counseling and computer-automated feedback groups also had access to an electronic diary and message board. The human email counseling group received weekly e-mail feedback from a counselor, and the computer-automated feedback group received automated, tailored messages. At 3 months, weight loss was greater for completers in both the computer-automated feedback group (mean 5.3 kg, SD 4.2 kg) and human email counseling group (mean 6.1 kg, SD 3.9 kg) compared with the no-counseling group (mean 2.8 kg, SD 3.5 kg), and the two intervention groups did not differ from each other. At 6 months, weight loss was significantly greater in the human email counseling group (mean 7.3 kg, SD 6.2 kg) than in the computer-automated feedback group (mean 4.9 kg, SD 5.9 kg) or no-counseling group (mean 2.6, SD 5.7 kg). Intent-to-treat analyses using single or multiple imputation techniques showed the same pattern of significance. Providing automated computer-tailored feedback in an Internet weight loss program was as effective as human email counseling at 3 months. 44

Another study examined the long-term effects of a new behavioral weight control program (Kenkoutatsujins, KT program) consisting of interactive communications twice in a month communications including computer-tailored personal advice on treatment needs and behavioral modification. Two hundred and five overweight Japanese women were recruited in an RCT comparing Group KM (KT program with 6-month weight and targeted behavior self-monitoring), Group K (KT program only), Group BM (an untailored self-help booklet with 7-month self-monitoring of weight and walking), and Group B (the self-help booklet only). Significant weight loss was observed in all groups. At 1 month, weight loss was greatest for Groups KM and K, but at 7 months, the mean weight loss was significantly more in Group KM than the other three groups. 17

To evaluate the efficacy of an Internet-based program for weight loss and weight-gain prevention, 446 overweight individuals (222 men; 224 women) with a mean age of 34 years and a mean BMI of 29 were recruited from a military medical research center with a population of 17,000 active-duty military personnel. Participants were randomly assigned to receive a 6-month behavioral Internet treatment (BIT, n=227) or usual care (n=224). After 6 months, completers who received BIT lost a mean of 1.3 kg while those assigned to usual care gained a mean of 0.6 kg (<0.001). 85

To determine the effectiveness of an Internet-based resource for obesity management, an RCT was conducted in a community setting, where obese volunteers were randomly assigned to an Internet group (n = 111) or usual care group (n =110). Data were collected at baseline, 6 months, and 12 months. Based on analysis conducted on all available data, the Internet group lost a mean of 1.3 kg, compared with a 1.9 kg weight loss in the usual care group at 12 months, a nonsignificant difference (difference = 0.6 kg; 95 percent CI: −1.4 to 2.5, p = 0.56). This trial failed to show any additional benefit of this Web site in terms of weight loss compared with usual care. 81

To test the efficacy of an Internet-based lifestyle behavior modification program for African American girls over a 2-year period of intervention, 57 overweight African American girls (mean BMI percentile, 98.3; mean age, 13.2 years) were randomly assigned to an interactive behavioral Internet program or an Internet health education program, the control condition. Overweight parents were also participants in the study. Forty adolescent-parent dyads (70 percent) completed the 2-year trial. In comparison with the control condition, adolescents in the behavioral program lost more mean body fat (BF) (−1.12 percent, SD 0.47 percent vs. 0.43 percent, SD 0.47 percent , p < 0.05), and parents in the behavioral program lost significantly more mean body weight (−2.43 kg, SD 0.66 kg vs. −0.35 kg, SD 0.64 kg, p<0.05) during the first 6 months. This weight loss was regained over the next 18 months. After 2 years, differences in BF for adolescents (mean −0.08 percent, SD 0.71 percent vs. mean 0.84 percent, SD 0.72 percent) and weight for parents (mean −1.1 kg, SD 0.91 vs. mean −0.60 kg, SD 0.89 kg) did not differ between the behavioral and control programs. An Internet-based weight management program for African American adolescent girls and their parents resulted in weight loss during the first 6 months but did not yield long-term loss due to reduced use of the Web site over time 83(Table 23, and Appendix G, Evidence Table 37).

### Mental Health

#### Summary of the Findings

Seven studies addressed the impact of CHI applications on mental health clinical outcomes (Table 25). Outcomes of interest include depression, anxiety, and serological measures. All of these studies were RCTs and received low scores according to the Jadad criteria (Appendix G, Evidence table 1). All of the studies indicated a positive impact of the CHI application on at least one of the reported outcomes. One study by Orbach et al133 showed a positive impact on anxiety but no impact on the Hem reasoning test or general self efficacy.

Table 25

Results of studies on CHI applications impacting clinical outcomes in mental health (N=7).

Target condition | N | Author, year | Interventions | Primary outcomes measured | Effect of CHI Application^*^
Mental Health | 7 | Christensen, 2004^†,99^ | Blue Pages: Computer based psycho education Web site offering information about depression MoodGYM: Computer based Cognitive Behavior therapy | Center for Epidemiologic depression scale | +
Mental Health | 7 | Hasson, 2005^100^ | Web-based stress management system | DHE-S | +
Mental Health | 7 | Hasson, 2005^100^ | Web-based stress management system | NPY | +
Mental Health | 7 | Hasson, 2005^100^ | Web-based stress management system | CgA | +
Mental Health | 7 | Hasson, 2005^100^ | Web-based stress management system | TNFα | +
Mental Health | 7 | Kerr, 2008^135^ | PACEi | CESD score | +
Mental Health | 7 | March, 2008^134^ | Web based intervention | Reduction in childhood anxiety | +
Mental Health | 7 | Orbach, 2007^133^ | Cognitive Behavior Therapy group (CBT) | Test Anxiety Inventory | +
Mental Health | 7 | Orbach, 2007^133^ | Cognitive Behavior Therapy group (CBT) | Anxiety Hierarchy Questionnaire | +
Mental Health | 7 | Orbach, 2007^133^ | Cognitive Behavior Therapy group (CBT) | Heim Reasoning Test | 0
Mental Health | 7 | Orbach, 2007^133^ | Cognitive Behavior Therapy group (CBT) | General Self-Efficacy Scale | 0
Mental Health | 7 | Proudfoot, 2003^137^ | beating the blues | BDI | +
Mental Health | 7 | Proudfoot, 2003^137^ | beating the blues | BAI | +
Mental Health | 7 | Proudfoot, 2003^137^ | beating the blues | Work and social adjustment scale | +
Mental Health | 7 | Spek, 2008^136^ | Group CBT Internet based intervention | Treatment response after 1 yr | +

* (+) positive impact of the CHI application on outcome; (−) negative impact of the CHI application on outcome; (0) no impact or not a significant of the CHI application on outcome

† positive impact was seen in both intervention groups, but was significant only in the MoodGym group

BDI= Beck depression inventory; BAI= Beck anxiety inventory; CBT = Cognitive behavioral therapy; CESD= Center for Epidemiological Studies Depression ; CgA=chromogranin A; DHE-S=dehydroeoiandosterone sulphate; NPY=nueropeptide Y; PACEi= Patient-centered Assessment and Counseling for exercise and nutrition via the Internet; TNFα = tumor necrosis factor α

#### Strengths and Limitations of the Evidence

The volume of this evidence is small, including only seven studies. Sample sizes in these studies ranged from very small (<20) in March et al134to greater than 100 participants in Chrstensen et al99, Ker et al135 and Hasson et al100 Followup periods were not reported in all seven studies, but where they were reported, they ranged from 6 weeks99 up to 12 months.135 Blinding, as measured by the Jadad criteria,4 was not reported in any of the studies (Appendix G, Evidence Table 1). The overall strength of the body of this evidence (Table 26) was graded as low based on a modified version of the GRADE criteria5 and Chapter 11 of the EPC Manual6

Table 26

Grade of the body of evidence addressing CHI impact on clinical outcomes in mental health.

1 | Protection against risk of bias | Low
2 | Number of studies | 7
3 | Did the studies have important inconsistency? y (−1); n (0) | 0
4 | Was there some (−1) or major (−2) uncertainty about the directness or extent to which the people, interventions and outcomes are similar to those of interest? Some (−1); major (−2); none (0) | 0
5 | Were the studies sparse or imprecise? y (−1); n (0) | 0
6 | Did the studies show strong evidence of association between intervention and outcome? “strong^*^” (+1); “very strong^†^” (+2); No (0) | 1
| Overall grade of evidence ‡ | Low

* if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders

† if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity

‡ (high, moderate, low):if above score is (+), increase grade; if above score is (−), decrease grade from high to moderate (−1) or low (−2).

#### Outcomes

A total of 191 women and 110 men (mean age 55 years, SD 4.6) with sub-threshold depression were randomized into Internet-based treatment, group CBT (Lewinsohn’s Coping with Depression Course) or a waiting-list control condition.136 The main outcome measure was treatment response after 1 year, defined as the difference in pretreatment and followup scores on the BDI. Simple contrasts showed a significant difference between the waiting-list condition and Internet-based treatment (p=0.03) and no difference between both treatment conditions (p=0.08).136

Another study assessed depressive symptoms in 401 participants in an RCT of a 12-month primary care, phone, and Internet-based behavioral intervention for overweight women. A one-way analysis of variance examining the mean change in Center for Epidemiological Studies Depression (CESD) score from baseline to 12 months, controlling for age, education, marital status, and employment, showed that those receiving the intervention significantly decreased their CESD scores (p<0.03) more than those receiving standard care.135

To evaluate the efficacy of an Internet-based cognitive-behavioral therapy (CBT) approach to the treatment of child anxiety disorders, 73 children with anxiety disorders, aged 7 to 12 years, and their parents were randomly assigned to either an Internet-based CBT (NET) or wait-list (WL) condition. The NET condition was reassessed at 6-month followup. At posttreatment assessment, children in the NET condition showed small but significantly greater reductions in anxiety symptoms and increases in functioning than WL participants. These improvements were enhanced during the 6-month followup period, with 75 percent of NET children free of their primary diagnosis. The conclusion was that Internet delivery of CBT for child anxiety offered promise as a way of increasing access to treatment for this population.134

To assess possible effects on mental and physical well-being and stress-related biological markers of a Web-based health promotion tool, 303 employees (187 men and 116 women, age 23–64 years) from four information technology and two media companies were enrolled. Half of the participants were offered Web-based health promotion and stress management training (intervention) lasting for 6 months. All other participants constituted the reference group. Clinical outcomes consisted of different biological markers measured to detect possible physiological changes. After 6 months, the intervention group had improved statistically significantly compared to the reference group on ratings of ability to manage stress, sleep quality, mental energy, concentration ability, and social support. The anabolic hormone dehydroepiandosterone sulphate (DHEA-S) decreased significantly in the reference group as compared to unchanged levels in the intervention group. Neuropeptide Y (NPY) increased significantly in the intervention group compared to the reference group. Chromogranin A (CgA) decreased significantly in the intervention group as compared to the reference group. Tumour necrosis factor α (TNFα) decreased significantly in the reference group compared to the intervention group.100

To test the hypothesis that CBT, available on the Internet, could reduce test anxiety, 90 university students were randomly allocated to CBT or a control program, both on the Internet. Before and after treatment, the participants completed the Test Anxiety Inventory (TAI), an Anxiety Hierarchy Questionnaire (AHQ), the Exam Problem-Solving Inventory (EPSI), the General Self-Efficacy Scale (GSES) and the Heim reasoning tests (AH) as a measure of test performance. Of the CBT and control groups 28 percent and 35 percent, respectively, withdrew. According to the TAI, 53 percent of the CBT group showed a reliable and clinically significant improvement with treatment but only 29 percent of the control group exhibited such a change. On the AHQ, 67 percent of the CBT group and 36 percent of the control group showed a clinically significant improvement, more than two standard deviations above the mean of the baseline, a change in favor of CBT. Both groups improved on the GSES, in state anxiety during exams retrospectively assessed, and on the AHQ tests. The study supported use of CBT on the Internet for the treatment of test anxiety. 133

A study by Christensen et al99 studied the impact of two different Internet interventions (MoodGym and BluePages) on community-dwelling individuals with symptoms of depression. To measure symptom change after the intervention, the 20-item CESD score was the primary outcome measure. The mean change in score was greater in the Internet intervention groups than in the control group. The difference was significant in the MoodGym group but not the BluePages group.

To measure the impact of the “beating the Blues” (BtB) interactive multimedia CBT program on anxiety and depression, Proudfoot et al 2003^137^ compared this program with usual treatment (or treatment as usual) for depression and anxiety. Three measures were used: the BDI, the BAI, and the Work and Social Adjustment (WSA) Scale. There was a significantly greater drop (of 5 points) in the BDI score in the BtB group compared to the usual care group. This drop was seen at 1 month post-intervention and was maintained over the six month followup period. Significance was not reported. A similar result was seen in the BAI score with a difference in reduction in score between the BtB group and usual care of 3 points. This change was sustained over the 6 month followup period. No significance was reported. Again, similar results were seen in the WSA score with a difference in reduction in score between the BtB group and usual care of 3 points. This change was sustained over the 6 month followup period. No significance was reported (Table 24, and Appendix G, Evidence Table 37).

### Miscellaneous Outcomes

#### Summary of the Findings

Ten studies evaluated the impact of CHI applications on clinical outcomes in various other health conditions (Table 27). Outcomes of interest included quality of life and disease-specific clinical outcomes. These outcomes were examined in the context of the following health problems: Alzheimer’s disease, arthritis, asthma, back pain, chronic adult aphasia, COPD, headache, HIV/AIDS, general pain, and obesity. The quality of these 10 studies was moderate to low.

Table 27

Studies of CHI applications impacting miscellaneous clinical outcomes (N=10).

Target condition | Number of studies | Author, year | Interventions | Primary outcomes measured
Alzheimer’s disease | 1 | Tarraga, 2006^139^ | IMIS,IPP, ChEIs IPP,ChEIs | Alzheimer’s Disease Assessment Scale-Cognitive
Arthritis | 1 | Lorig, 2008^114^ | Online intervention | Health distress
Arthritis | 1 | Lorig, 2008^114^ | Online intervention | Activity limitation
Arthritis | 1 | Lorig, 2008^114^ | Online intervention | Self reported global health Pain
Arthritis | 1 | Lorig, 2008^114^ | Online intervention | Self efficacy
Asthma | 1 | Jan, 2007^10^ | Participants received asthma education and with interactive asthma monitoring system | Symptom score at nighttime
Asthma | 1 | Jan, 2007^10^ | Participants received asthma education and with interactive asthma monitoring system | Symptom score at daytime
Asthma | 1 | Jan, 2007^10^ | Participants received asthma education and with interactive asthma monitoring system | Morning PEF
Asthma | 1 | Jan, 2007^10^ | Participants received asthma education and with interactive asthma monitoring system | Night PEF
Back Pain | 1 | Buhrman, 2004^115^ | Cognitive Behavior Intervention | CSQ-Catastrophizing
Back Pain | 1 | Buhrman, 2004^115^ | Cognitive Behavior Intervention | CSQ-Ability to decrease pain
Back Pain | 1 | Buhrman, 2004^115^ | Cognitive Behavior Intervention | CSQ-Control over pain
Chronic Adult Aphasia | 1 | Katz, 1997^140^ | Computer reading treatment Computer stimulation | Porch Index of Communicative Ability (percentiles): Overall
Chronic Adult Aphasia | 1 | Katz, 1997^140^ | Computer reading treatment Computer stimulation | Porch Index of Communicative Ability (percentiles): Verbal
Chronic Adult Aphasia | 1 | Katz, 1997^140^ | Computer reading treatment Computer stimulation | Western Aphasia Battery Aphasia “Quotient”
Chronic Adult Aphasia | 1 | Katz, 1997^140^ | Computer reading treatment Computer stimulation | Western Aphasia Battery Aphasia “Repetition”
COPD | 1 | Nguyen, 2008^110^ | Electronic dyspnea self management program | Score on CRQ subscale for dyspnea with ADLs
Headache | 1 | Trautman, 2008^141^ | CBT | Frequency
Headache | 1 | Trautman, 2008^141^ | CBT | Duration
Headache | 1 | Trautman, 2008^141^ | CBT | Intensity
Headache | 1 | Trautman, 2008^141^ | CBT | Pain catastrophizing
HIV/AIDS | 1 | Gustafson, 1999^142^ | CHESS | Active life
HIV/AIDS | 1 | Gustafson, 1999^142^ | CHESS | Social support
HIV/AIDS | 1 | Gustafson, 1999^142^ | CHESS | Participation in health care
Obesity | 1 | Morgan, 2009^91^ | Tailored Web-site | Change in body weight at 3 and 6 months
Obesity | 1 | Morgan, 2009^91^ | Tailored Web-site | Change in waist circumference at 3 and 6 months
Obesity | 1 | Morgan, 2009^91^ | Tailored Web-site | BMI at 3 and 6 months
Obesity | 1 | Morgan, 2009^91^ | Tailored Web-site | Systolic blood pressure at 3 and 6 months
Obesity | 1 | Morgan, 2009^91^ | Tailored Web-site | Diastolic blood pressure at 3 and 6 months
Obesity | 1 | Morgan, 2009^91^ | Tailored Web-site | Resting heart rate at 3 and 6 months
Pain | 1 | Borckardt, 2007^143^ | CACIS | Cold Pressor Tolerance

IMIS=interactive multi-media Internet-based system; IPP= integrated psychostimulation program; ChEIs = cholinesterase inhibitors; PEF= peak expiratory flow; CSQ= coping strategies questionnaire; CRQ= chronic respiratory questionnaire; ADL= activities of daily living; FBS= fasting blood sugar; FBG= fasting blood glucose; TC = total cholesterol; TG= triglycerides; BIT= behavioral Internet treatment; BMI= body mass index: CHESS= Comprehensive Health Enhancement Support System; CACIS computer assisted cognitive imagery system

#### Strengths and Limitations of the Evidence

The literature in this area had significant limitations. There were only a few studies for each particular condition. The disease-specific clinical outcomes evaluated for the same condition in different studies were not fully comparable. The same problem was true of the general quality of life measures used across various conditions in different studies. This limited the possibility of cross-study comparisons. The quality of these trials was variable with some studies lacking in one or more methodological domains of RCT quality as measured by the Jadad4 criteria (Appendix G, Evidence Tables 35–37). The majority of the studies did not fully comply with CONSORT138guidelines or had low study quality scores. Several studies were based on a very small sample size or relied on a short follow up period. Sample size varied from as little as 16 in an entire study to 651. Postintervention evaluations ranged from as little as 6 weeks to as many as 24 months. Although there was sparse data for each target condition within this category of outcomes, we felt that grading the evidence was important due to the large number f studies. The overall strength of the body of this evidence was not graded as it was too heterogeneous.

#### Outcomes

##### Alzheimer’s disease

This was a 24-week study of 46 mildly impaired patients suspected of having Alzheimer’s disease receiving stable treatment with cholinesterase inhibitors (ChEIs). The patients were divided into three groups: 1) those who received three weekly, 20-min sessions of interactive multimedia Internet-based system (IMIS) in addition to eight hours per day of an integrated psychostimulation program (IPP); 2) those who received only IPP sessions; and 3) those who received only ChEI treatment. The primary outcome measure was the Alzheimer’s Disease Assessment Scale-Cognitive (ADAS-Cog). Secondary outcome measures were: Mini-Mental State Examination (MMSE), Syndrome Kurztest, Boston Naming Test, Verbal Fluency, and the Rivermead Behavioral Memory Test story recall subtest. Although both the IPP and IMIS improved cognition in patients with Alzheimer’s disease, the IMIS program provided an improvement above and beyond that seen with IPP alone, which lasted for 24 weeks139(Appendix G, Evidence Table 37).

##### Arthritis

To determine the efficacy of an Internet-based Arthritis Self-Management Program (ASMP), randomized intervention participants were compared with usual care controls at 6 months and 1 year using repeated-measures analyses of variance. Patients with rheumatoid arthritis, osteoarthritis, or fibromyalgia and Internet and email access (n=855) were randomized to an intervention (n=433) or usual care control (n=422) group. Measures included six clinical outcomes: pain, fatigue, activity limitation, health distress, disability, and self-reported global health. At 1 year, the intervention group significantly improved in four of six clinical outcomes as compared to baseline: health distress (p<0.001), activity limitation (p < 0.001), self-reported global health (p<0.004), and pain (p<0.001). The Internet-based ASMP proved effective in improving clinical outcomes in arthritis patients114 (Appendix G, Evidence Table 37).

##### Asthma

To assess an Internet-based interactive asthma educational and monitoring program used in the management of asthmatic children, 164 pediatric patients with persistent asthma were enrolled and randomized into two study groups for a 12-week controlled trial. The intervention group had 88 participants who were taught to monitor their peak expiratory flows (PEF) and asthma symptoms daily on the Internet. Clinical outcomes were assessed by weekly averaged peak expiratory flow (PEF) values, symptom scores, asthma control tests, and quality of life. At the end of trial, the intervention group decreased the nighttime symptom score (range: 0=no asthma symptoms, 1=symptoms occurred several times but do not interfere with daily activities, 2=symptoms interfere with daily activities, 3= symptoms interfere with all activities), (mean change −0.08, SD 0.33 vs. 0.00, SD 0.20, p<0.028) and daytime symptom score (mean change −0.07, SD 0.33 vs. 0.01, SD 0.18, p<0.009); improved morning PEF (mean change 241.9 L/min, SD 81.4 vs. 223.1L/min, SD 55.5, p<0.017) and night PEF (mean change 255.6 L/min, SD 86.7 vs. 232.5 L/min, SD 55.3, p<0.010); improved the rate of having well-controlled asthma (70.4 percent vs. 55.3 percent, p<0.05); and improved quality of life on a 7-point scale (mean 6.5, SD 0.5 vs. 4.3, SD 1.2, p<0.05) when compared with conventional management. The Internet-based asthma telemonitoring program improved clinical outcomes in pediatric asthma patients10 (Appendix G, Evidence Table 37).

##### Back pain

To investigate the effects of an Internet-based CBI with telephone support for chronic back pain, 56 subjects with chronic back pain were randomly assigned to either an Internet-based cognitive-behavioral self-help treatment or to a waiting-list control condition. The study period lasted 8 weeks and consisted of 1 week of self-monitoring prior to the intervention, 6 weeks of intervention, and 1 week of postintervention assessment. Treatment consisted of education, cognitive skill acquisition, behavioral rehearsal, generalization, and maintenance. The study showed statistically significant improvements in catastrophizing, control over pain, and ability to decrease pain. The findings indicated that Internet-based self-help with telephone support, based on established psychological treatment methods, holds promise as an effective approach for treating disability in association with pain 115 (Appendix G, Evidence Table 37).

##### Chronic adult aphasia

To examine the effects of computer-provided reading activities on language performance in chronic aphasic patients, 55 aphasic adults were assigned randomly to one of three conditions: computer reading treatment, computer stimulation, or no treatment. Subjects in the computer groups used a computer 3 hours each week for 26 weeks. Computer reading treatment software consisted of visual matching and reading comprehension tasks. Computer simulation software consisted of nonverbal games and cognitive rehabilitation tasks. Language measures were administered to all subjects at entry and after 3 and 6 months. Significant improvement over the 26 weeks occurred on five language measures for the computer reading treatment group, on one language measure for the computer stimulation group, and on none of the language measures for the no-treatment group. The computer reading treatment group displayed significantly more improvement on the Porch Index of Communicative Ability “Overall” and “Verbal” modality percentiles and on the Western Aphasia Battery “Quotient” and “Repetition” subtest than the other two groups140 (Appendix G, Evidence Table 37).

##### COPD

One study tested the efficacy of two 6-month dyspnea self-management programs, Internet-based (eDSMP) and face-to-face (fDSMP), on dyspnea with activities of daily living (ADL) in people living with COPD. Fifty participants with moderate to severe COPD who were current Internet users were randomized to either the eDSMP (n = 26) or fDSMP (n = 24) group. The content of the two programs was similar, focusing on education, skills training, and ongoing support for dyspnea self-management, including independent exercise. The only difference was the mode (Internet/personal digital assistant [PDA] or face-to-face) in which the education sessions, reinforcement contacts, and peer interactions took place. The primary clinical outcome was dyspnea with ADL that was measured with the Chronic Respiratory Questionnaire. The study was stopped early due to multiple technical challenges with the eDSMP, but followup was completed on all enrolled participants. Analysis of data available from the remaining 39 participants did not show significant differences between intervention and control groups110 (Appendix G, Evidence Table 37).

##### Headache

Sixteen participants participated in a study to compare the efficacy of an on-line cognitive behavioral treatment (CBT) program with an Internet-based psychoeducational 141 intervention using chat groups (control) on pediatric headache. The main outcome measures were frequency, duration, intensity, and pain catastrophization. There were no significant differences in changes between the groups for all of the outcome measures. However, the frequency of headaches in the CBT group postintervention decreased. Headache duration and intensity did not change significantly for the CBT group. Pain catastrophizing was reduced significantly post treatment. At the 6-month followup, the treatment effects had not diminished (Appendix G, Evidence Table 37).

##### HIV/AIDS

To test a computerized system (CHESS: Comprehensive Health Enhancement Support System), which provided HIV-positive patients with information, decision support, and connections to experts and other patients, 204 HIV-positive patients (90 percent male, 84 percent White, most having at least some college education, and 65 percent experiencing HIV-related symptoms) were randomized to an intervention group (CHESS computers in experimental subjects’ homes for 3 or 6 months) or control group (no intervention). The following quality of life sub-scores were significantly different between control and intervention groups in 6-month followup: active life (1.37 vs. 1.66, p<0.034), social support (4.24 vs. 4.47, p<0.017), and participation in health care (3.64 vs. 4.15, p<0.020)142 (Appendix G, Evidence Table 37).

##### Pain

This study was designed to compare the effectiveness of a computerized pain management program over a distraction control. A computer-assisted cognitive/imagery system (CACIS) was used to assist subjects in pain management.143 The control group used an identical system as the intervention group; the difference between the two being the control group group received a prerecorded story about migratory bird patterns with no animation in the visual presentation. The intervention group heard a male voice framing the experience as unpleasant instead of painful. An individual’s pain was animated on the screen. Each group was subjected to an ice water bath for up to 150 seconds, depending on pain tolerance. The intervention group was able to tolerate the cold for 13 seconds longer than the control group, but this was not a significant difference (Appendix G, Evidence Table 37).

## Key Question 1e. What evidence exists that consumer health informatics applications impact economic outcomes?

### Summary of the Findings

Three studies evaluated the impact of CHI applications on economic outcomes (Table 28). These outcomes were examined in the context of 3 health problems including asthma, cancer (breast, cervical prostate and laryngeal), and obesity. Studies were very heterogeneous in respect to their target areas of interest and outcomes. They will be discussed individually below.

Table 28

Studies of CHI applications impacting economic outcomes (N=3).

Target condition | Number of studies | Author, year | Interventions | Primary outcomes measured
Asthma | 1 | Joseph, 2007^15^ | Treatment | Cost of program delivery to developers
Cancer, breast, cervical prostate, and laryngeal | 1 | Jones, 1999^109^ | General computer information Tailored computer information | Cost of the computer information system—Manual extraction of Patient data
Cancer, breast, cervical prostate, and laryngeal | 1 | Jones, 1999^109^ | General computer information Tailored computer information | Cost of the computer information system—use of electronic patient record
Cancer, breast, cervical prostate, and laryngeal | 1 | Jones, 1999^109^ | General computer information Tailored computer information | Materials cost
Obesity | 1 | McConnon, 2007^81^ | Web site (Internet group) | Total costs to user
Obesity | 1 | McConnon, 2007^81^ | Web site (Internet group) | Incremental cost-effectiveness

### Strengths and Limitations of the Evidence

Three studies evaluated six domains of CHI impact on economic outcomes. All of the studies addressing economic outcomes had relatively large sample sizes: greater than 300 for the study on asthma,109 152 in the control arm,162 in the intervention arm; greater than 450 in the study on cancer,15 162 in the control arm, 143 in the general information arm, and 162 in the tailored intervention; and more than 100 participants in the study on obesity81 (Appendix G, Evidence Tables 38–40). The quality of these 3 trials was low to moderately low with studies lacking in one or more methodological domains of RCT quality as measured by the Jadad criteria 4 (Appendix G, Evidence Table 1). The body of evidence was not graded for this sub-question due to the small number of studies.

### General Study Characteristics

The studies that were evaluations of the impact of CHI applications on economic outcomes generally were tested on an adult population (mean age: 47.4–48.1 years) in the study addressing obesity,81 on a juvenile population in the study on asthma (mean age 15.3 years),109 and not specified in the study on cancer.15 Information regarding gender was only reported in the paper on asthma where 63 percent of the population was female.109 None of the studies reported on the race/ethnicity, or socioeconomic status (SES) of study participants. The asthma study109 reported on smoking status of greater than or equal to 2 cigarettes per day in 5.2 percent of the population, and the obesity study81 reported on weight, BMI, quality of life, and physical activity in each of the study groups (Appendix G, Evidence Tables 38 and 39).

### Outcomes

#### Asthma

The economic measure in the study on asthma was identified as the “cost of program delivery.” At the end of the study period (12 months), the cost of the referral coordinator (the only measurable cost of the study) was $6.66 per treatment per student. There was no cost estimate for the control group 109 (Appendix G. Evidence Table 40).

#### Cancer: breast, cervical, prostate, and laryngeal

There were three measures of cost in the study on cancer. The first measure was the actual cost of implementing the computer information system using manual entry of patient data. The authors found that the cost to manually extract patient data into a computer information system would cost 9 times as much as the control or a general information site. The next measure identified the cost of importing the electronic patient record into the tailored information system. There was no difference found in cost between the general information system and the tailored system using this method. The final measure of cost studied was material cost. The control group used paper (books) and the cost per book was estimated at £7. The cost of the general information system was estimated to be 40 percent of this, or £2.8 per patient. No information was provided for per user cost of the tailored information system15 (Appendix G. Evidence Table 40).

#### Obesity

The obesity study measured total costs and incremental cost effectiveness. The total cost for the control group was £276.12 compared to the total cost for the Web site intervention group of £992.40. The authors pointed out that the difference in cost was due to the cost of developing the Web site. They stated that when this fixed cost was removed, the total costs of the intervention were lower. However, the actual estimate was not reported. Incremental cost-effectiveness was calculated for the intervention group, and was reported as £39,248 per quality-adjusted life-year81 (Appendix G. Evidence Table 40).

## Key Question 2: What are the barriers that clinicians, developers, and consumers and their families or caregivers encounter that limit implementation of consumer health informatics applications?

Thirty-one studies were reviewed that addressed the barriers to CHI applications, with a focus on studies that reported on CHI applications that were individualized to the consumers’ or caregivers’ needs. Documented barriers to CHI applications were identified, extracted, and tabulated.

### Disease/Problem Domain

The CHI applications focused on a specific disease or problem domain. Two studies addressed more than one disease (breast cancer – all cancers144; HIV/AIDS – STDs145), but the remaining 20 studies focused on only one disease or problem domain. Diseases included breast cancer (4), 144,146–148 mental health (3),149–151 physical activity/diet/obesity (4),36,152–154 diabetes (3),93,155,156 HIV/AIDS (2),145,157 prostate cancer (1),158 all cancers (1),144 hypertension (1), 159 STDs (1).145 Problem domains included use of a personal health record (3)160–162 and review of systems (1).163

For the purpose of further analysis, the study focusing on breast cancer and all cancers 144 was collapsed under “all cancers” (leaving three breast cancer related studies) and the study dealing with HIV/AIDS and STDs145 under HIV/AIDS (leaving no study on STDs) (Appendix G, Evidence Tables 41–43).

### Methodology

The methodology used to identify barriers varied across studies (Tables 29 and 30). There were four categories including validated survey, nonvalidated survey, qualitative research, and empirical research. Five studies used more than one methodology. 36,145,150,153,160 If a study used either a validated survey or empirical research, it was collapsed under “Validated survey /Empirical.” Otherwise, it was assigned “Nonvalidated survey /Qualitative” as the research methodology (Appendix G, Evidence Tables 41–43).

Table 29

The distribution of methodologies for identifying barriers to the use of consumer health informatics by disease /problem domain.

Methodology Disease | Non-validated survey /Qualitative | Validated survey /Empirical | Total
All Cancers | 2 | | 2
Breast Cancer | 1 | 2 | 3
Diabetes | 5 | | 5
HIV/AIDS | 3 | | 3
Hypertension | 1 | | 1
Mental Health | | 3 | 3
Personal health record | 2 | 1 | 3
Physical Activity / Diet / Obesity | 6 | 1 | 7
Prostate Cancer | 1 | | 1
Review of systems | 1 | | 1
Smoking Cessation | 2 | | 2
Total | 24 | 7 | 31

Table 30

The distribution of methodology by barrier type.

Methodology Barrier | Non-validated survey / Qualitative | Validated survey / Empirical | Total
Systems & User Level | 6 | 1 | 7
Systems level | 3 | 2 | 5
User level | 15 | 4 | 19
Total | 24 | 7 | 31

CHI applications require participation of consumers, their caregivers, clinicians, and developers. Barriers can apply to any of the participants, and the type and impact of the barrier may vary significantly between providers, developers, patients, and their caregivers. Thus, an analysis of the barriers must include those that impede participation of any of the above groups.

### Barriers

Barriers were divided between system-level and the individual-level barriers (Table 31):

1. System-level barriers were further divided into technical or health care system issues. Technical barriers included usability, work flow issues, and data security concerns. Health care system issues included the reimbursement system and incompatibility between patient applications and legacy systems in health care institutions.
2. Individual level barriers pertained to either the clinician or the consumer. Clinician endorsement affects consumer choice, and thus negative attitudes of clinicians may be a barrier to consumer use. Consumer issues included lack of access to the application (e.g., no home Internet access), concerns about privacy, limited literacy and knowledge, language hurdles, cultural issues, and lack of technologic skills (Appendix G, Evidence Tables 41–43).

Table 31

The distribution of barrier levels by disease/problem domain.

Barrier | Both levels | Systems level | User level | Total
Disease/Problem Domain
All Cancers | | 1 | 1 | 2
Breast Cancer | | | 3 | 3
Diabetes | 2 | | 3 | 5
HIV/AIDS | 1 | | 2 | 3
Hypertension | | | 1 | 1
Mental Health | 1 | 1 | 1 | 3
Personal health record | 2 | | 1 | 3
Physical Activity / Diet / Obesity | | 3 | 4 | 7
Prostate Cancer | | | 1 | 1
Review of systems | 1 | | | 1
Smoking Cessation | | | 2 | 2
Total | 7 | 5 | 19 | 31

#### System-level barriers

##### Technical system-level barriers

Nine studies explored lack of Internet access at home or in the community and six found this to be a barrier147,152,153,156,159,160 (Appendix G, Evidence Table 43). One study identified hardware requirements as a systems level barrier.164 and another study identified mobile device shape/design/configuration as a systems level barrier.165

##### Health care system-level barriers

Five studies cited incompatibility with current care as a barrier145,157,159,160,163 (Appendix G, Evidence Table 43).

#### Individual-level barriers

##### Clinicians

One study noted that the clinic staff feared more work. 151 Of note, the applications that were included in the literature review were applications that are operated independently by consumers, so there are no applications that require the physician to interact directly with the consumer through a CHI application (Appendix G, Evidence Table 43).

##### Developers

One study cited lack of built-in social support in the CHI application as a barrier. 93 One study noted that patients forgot their passwords by the time they had their followup visit. 151 One study cited lack of training and guidance in the use of the application. 160 Along the same lines, one study reported that electronic tools for data entry were a problem for users 144, whereas another cited the lack of automated data entry as a problem. 155 In one study users complained about a design that did not allow for back entry of old data.165 Two studies discussed lack of user customization or making the content more relevant to the consumer and his or her community as a barrier93,154 (Appendix G, Evidence Table 43). Two studies focused on the “substantial investment” required for the development and maintenance of CHI resources.75,166

##### Consumers and their caregivers

Nineteen studies queried application usability or user-friendliness and all nineteen found evidence of this barrier36,147–149,151–158,160,161,163,167–169(Appendix G, Evidence Table 43).

Eleven studies explored patient knowledge, literacy, and skills to use the CHI application. Deficits in these areas were found by one study not to be a barrier. 146 The other ten, plus one study that had not initially considered these barriers in the study design, did find these deficits to be barriers 144,148,150,151,156,157,159–163 (Appendix G, Evidence Table 43).

Six studies considered the possibility that users would find the application too time-consuming and five of these reported this barrier in the results section. 152 In the same vein, one study cited too many emails to participants as a barrier.169One study queried consumers about the acceptability of fees for use of an interactive portal and found that most participants were not willing to pay any fee for the service.166

Five studies sought information about privacy concerns and four reported concerns over privacy as a barrier in their finding.144,145,151,161 The same four studies queried and found concerns over the control of information or lack of trust to be barriers144,145,151,161(Appendix G, Evidence Table 43).

Two studies queried for cultural barriers and only one study found evidence of this. 146 One study found the language of the CHI application to be a barrier. 161

The expectations of consumers figured prominently in the barriers analysis. The terms acceptability, usefulness, credibility, expectations, and goals were mentioned often and the lack thereof was found to indicate barriers in eight studies 20,93,165,167 36,147,151,157(Appendix G, Evidence Table 43).

One study of an interactive Web portal did not identify a barrier regarding usefulness, but found that most participants who had not used the portal expected a number of features to be useful, but less users of the portal actually rated these features as useful.166

Cost was mentioned as a barrier in only one study.165

Three studies investigated consumer disability, generally grouped as physical or cognitive. One did find evidence that physical or cognitive impairment resulted in barriers to the use of CHI applications. 162 One found that not reacting to visual preferences was a barrier. 158 Anxiety over the use of computers, complaints about lack of personal contact with clinicians and the belief that IT would not be an improvement to current care were mentioned in two studies as barriers159,162 (Appendix G, Evidence Table 43).

## Key Question 3: What knowledge or evidence deficits exist regarding needed information to support estimates of cost, benefit, and net value with regard to consumer health informatics applications?

Upon review of the results of the systematic review presented above, several important knowledge gaps became evident. In general, the literature was at a very early stage of development. Many questions have only been evaluated by one study. Thus, confirmatory studies have generally not been done. In addition, no high quality studies have been conducted regarding several important questions. Broadly, these questions can be grouped into at least one of the following four categories: patient-related questions, CHI utilization factors, technology/hardware/software/platform-related issues, and health-related questions. The major questions and outstanding issues of concern for each of these sections will be outlined below.

### Patient-related Questions

Many questions about CHI applications at the patient level remain. The results of our review suggested that the literature is relatively silent on the question of whether or not significant differences in patient preferences, knowledge, attitudes, beliefs, needs, utilization, and potential benefits exists across gender, age, and race/ethnicity. Intuitively, we suspect some differences exist, especially as they relate to the senior population compared to the adolescent population. However, these differences have not been definitively characterized, and the clinical and public health implications of these differences are largely unknown. The same could be said for potential gender- and race or ethnicity-based differences. Early evidence suggests that potentially significant differences exist that could have important health implications as we move toward a more technology-saturated society.170,171 Beyond these potential demographic differences, the emerging field of CHI is developing within the context of a societal and even global emergence of technology-based realities, including Web 2.0/Web 3.0 and ubiquitous computing, which are enabling an unprecedented level of user-determined interactivity and functionality. The degree to which this functionality could be harnessed for the health benefit of consumers is largely unknown. Along these lines, with the predominance of chronic diseases and the burgeoning of the senior population in this country, there is an increasing reliance on nonprofessional family, community, and low-skilled caregivers providing ever increasing levels of care to patients. As such, the target users of CHI applications must increasingly be focused on more than just the index patient. Our review suggested that the majority (but not all) of the current RCT CHI literature is focused on the patient as the CHI user. Finally, given the increasing role of family members, friends, and other caregivers, sociocultural and community factors will likely exert significant impact on access, usability, desirability, and benefit of CHI applications. Issues related to trust, security, and confidentiality need to be further explored.

### CHI Utilization-related Factors

Given the ubiquity of the Internet, the overwhelming majority of current and developing CHI applications will likely be reliant at least in part on the Internet. Increasingly this will require that consumers have broadband access to the Internet to take advantage of the full functionality that CHI applications potentially have to offer. Despite a rapid increase in both the availability and access to broadband services among all population groups, age groups, and geographic regions of the country (eHealth Solutions for Health Care Disparities Gibbons (ed) 2007 Springer Pub), differential access to broadband Internet access may have significant implications in terms of health benefits that may be derived from these tools and applications. Of equal concern, while many in the younger generations become very technically savvy at an early age, many Americans still have limited health literacy (eHealth Solutions for Health Care Disparities Gibbons (ed) 2007 Springer Pub). The combination of low technology expertise and low health literacy may pose insurmountable barriers for some individuals. The ability of these individuals to use and benefit from CHI applications, even when adequate access exists, should be evaluated. Taken together then, these CHI utilization factors suggest the need for a more robust evaluation and explication of the epidemiology of broadband access and technology literacy in the US.

### Technology/Hardware/Software/Platform-Related Issues

The results of our review suggest that the majority of currently evaluated CHI tools and applications are designed for use on personal computers (desktop, laptop) as Web-based applications. While these technology platforms have certainly not been exhaustively studied, many more potential platforms exist, including interactive webTV, Video On Demand, smartphones, and health gaming to name a few. In the domestic literature, the potential of these platforms has not been evaluated. In addition, it appears that the CHI applications evaluated to date have been designed primarily by health care practitioners without sufficient training or expertise in critical design areas such as human factors and user-centered design. As such, currently available tools may not be the best possible tools and may yield disappointing results despite well-designed evaluation studies. Emerging evidence from the Robert Wood Johnson Foundation’s Project HealthDesign and other similar projects is suggesting that the CHI tools and applications and functionality that consumers want and need are not always what health care practitioners think they need.172 Furthermore, many health care practitioners and entrepreneurs are likely ill-equipped to integrate the appropriate data, as suggested above, into the design process. As a result, important sociocultural and human computer interface design elements may not get incorporated adequately into emerging CHI applications and therefore may lead to CHI applications with limited efficacy.

### Health-related Factors

Finally, the results of our review suggested that several important health-related questions remain regarding the potential utility of CHI applications. To date, most CHI applications that have been evaluated tend to focus on one or more domains of chronic disease management. While this is very important and clearly needed, insufficient attention has been given to the role of CHI applications in the acute exacerbation of symptomatology or other urgent and emergent problems that may occur in home- and community-based settings. While it remains clear that professional expertise is increasingly needed as the acuity of the problem increases, with the growing dominance of home- and community-based care and self-management, telephone and/or ambulance transfer to an emergency room may not represent the most efficient and cost effective way to access professional health care personnel and services. Along these lines, the role of CHI applications in primary, secondary, and tertiary prevention needs to be more adequately explored. Given the prevalence of mental health and psychiatric issues, the value of CHI applications in the context of mental health, coping, and stress should be evaluated. Finally sociocultural factors are increasingly important determinants of health care outcomes. The potential impact on social factors including social isolation and social support and perhaps even broader social determinants of health need to be evaluated and may prove useful in helping patients address select health concerns in the home- and community-based setting.

## Key Question 4: What critical information regarding the impact of consumer health informatics applications is needed in order to give consumers, their families, clinicians, and developers a clear understanding of the value proposition particular to them?

The results of the current review suggest that several critical information needs still exist that must be filled to enable a clear understanding of the value proposition of CHI applications. It is likely that the knowledge gaps needed to establish a value proposition, while overlapping, are not identical across all potential stakeholders. We will address this question from 2 perspectives, that of the clinician or provider and that of the patient, family and caregiver.

### Clinician and Provider Value Proposition Information Needs

While this review focused on CHI applications that are not dependent on a clinical provider, they at times may involve providers. It is well known that provider recommendations and support can be an important motivator for some patients to engage in a certain behavior. It may be that provider recognition and support of patient use of CHI could play an important role in the adoption and use of CHI applications by some patients. Because providers are often most concerned about clinical outcomes and costs, it seems reasonable that questions of the impact of CHI applications on provider or health care processes, costs, and outcomes as addressed in this report will need to be more definitively characterized. There is at least one additional critical knowledge need that is pertinent to providers. It is the potential liability a provider might incur from a patient using a CHI application. It is not clear at this point that any liability would exist under current law, particularly for those CHI applications that do not involve a health care professional. Yet it may be that this question will need some further clarification prior to widespread endorsement of CHI applications by many health care providers.

### Patient, Family, and Caregiver Value Proposition Information Needs

While it is tempting to believe that patients want the exact same thing as their providers and health care practitioners, we know that this is not always the case. Indeed the growth of the Internet and its utilization first by consumers and then providers can be very instructive regarding value proposition needs of consumers.173 This data and experience suggest that patients and caregivers are, except in the cast of an emergent problem, often most concerned with well-being issues, health care processes, costs, and then clinical outcomes. Patients most often cite convenience and anonymity as the primary reasons the Internet has become such a major source of health information.173 Interestingly, both of these characteristics are largely lacking from our health care system today. It is likely that the more these elements can be incorporated into emerging CHI applications, the more likely they will be considered of value by consumers. Other related factors such as usability, portability, and patient-centered functionality are likely important characteristics of CHI applications that may help drive utilization. It has been suggested that the degree to which technology becomes “invisible,” or becomes incorporated into an individual’s lifestyle rather than creating additional tasks or processes, is the degree to which these tools will become more powerful. Those technologies that exist and enable consumers to accomplish tasks (empower) without further complicating individuals lives may ultimately prove to be the most widely used and valued CHI applications. Finally, by expanding the list of available platforms from which consumers can utilize CHI tools and applications (TV, WebTV, satellite, On Demand, health gaming), CHI applications may become more appealing to a broader consumer base and thus prove valuable to those consumers who could most benefit, but may not otherwise use a more traditional CHI application.

## Research in Progress

Based on a search string developed early in the development of the project (see Appendix C), a similar search string was developed to search the grey literature for ongoing research (Health Services Research Projects in Progress database). Our search identified 180 titles that were reviewed for relevance to our study topic. Four ongoing and continuing research studies were identified. The outcomes in these studies may provide additional information about the success of a consumer-centered approach to health care. All these studies were designed to develop Internet-based health informatics that in the end will be helpful in improving the quality of care and creating a more informed consumer. The results of these studies have not been published yet.

One study by Christakis,171 is an ongoing study to develop an Internet-based patient-centered asthma management system. A critical feature of the study is to improve the quality of asthma care delivery by health care providers. The study will gauge the effectiveness of AsthmaNet, a Web-based asthma patient activation system, which will provide tailored clinical information to parents as well as give them decision aids to share with their providers.

In another study, which was completed in 2008, Lorig et al174 evaluated the usefulness of translating evidenced-based small-group diabetes education on to an Internet platform. The main aims of the 2-year RCT were to: 1) develop, implement, and evaluate an Internet Diabetes Self-Management Program (IDSMP) compared with usual care; 2) compare the effects of the IDSMP with and without email discussion group reinforcement; 3) conduct cost-benefit analysis of the IDSMP compared with usual care, and the IDSMP with and without reinforcement; and 4) conduct a process evaluation of the use of the sections of the IDSMP and how usage, changes in behaviors, changes in self-efficacy, and patient characteristics are associated with intervention effects (health status and health care utilization) at 6 months and 2 years.

Another completed study completed in 2005, by Col175 was designed to address the issues involved with menopause. The immediate goal was to develop a technology comprehensive Menopause Interactive Decision Aid System (MIDAS) that provides personalized feedback about menopausal symptoms, risks for common conditions, and the effects of different treatment options on the short- and long-term consequences of menopause. The main hypotheses of this study are that MIDAS can: 1) lead to better decisions and improve the quality of menopausal counseling; 2) improve compliance with a chosen menopausal plan; and 3) reduce medical errors associated with the use of menopausal therapies. The specific aims are to: 1) develop and optimize the utilization of MIDAS; 2) evaluate the impact of MIDAS on the decisionmaking process, including decisional conflict, knowledge, risk perception, anxiety, patient-physician communication, satisfaction with decisionmaking, the quality of menopause counseling, and medical errors related to menopausal therapy; and 3) evaluate the long-term impact of MIDAS on outcomes related to menopause.

In another study, which was completed in 2008, Sciamanna,176 studied the efficacy of a computer program that creates: 1) patient-specific physical activity self-help reports for individuals, and 2) patient-specific reports to prompt and guide physician advice. The study was designed to assess the effects of the computer-generated physical activity reports (patient and physician) on the patients’ physical activity and endurance fitness over a 6-month period as compared with usual care.