# Appendix G

Evidence Table 1

Jadad criteria for RCT quality

Author, year | Target | RCT | Approp of rand. | Blinding | Approp of blinding | WD | SCORE
Key Question 1 a (healthcare process outcomes)
Bartholomew et al.^1^ | Asthma | 1 | 0 | −1 | | −1 | −1
Guendelman et al.,^2^ | Asthma | 1 | 0 | 0 | | 1 | 2
Jan, 2007^3^ | Asthma | 1 | 0 | −1 | | 1 | 1
Krishna, 2003^4^ | Asthma | 1 | | 1 | | 1 | 3
Chewining, 1999^5^ | Oral contraception use | 1 | −1 | | | 0 | 0
Key Question 1 b (intermediate outcomes)
Gustafson, 2008^6^ | Breast cancer | 1 | 1 | | | 0 | 2
Gustafson, 2001^7^ | Breast cancer | 1 | | | | 0 | 1
Jones, 1999^8^ | Breast cancer | 1 | | −1 | | 1 | 1
Adachi, 2007^9^ | Diet, exercise, physical activity (not obesity) | 1 | −1 | | | 0 | 0
Anderson, 2001^10^ | Diet, exercise, physical activity (not obesity) | 1 | −1 | 0 | | 1 | 1
Bruge, 1996^11^ | Diet, exercise, physical activity (not obesity) | 1 | | | | 1 | 2
Brug, 1998^12^ | Diet, exercise, physical activity (not obesity) | 1 | 0 | 0 | | −1 | 0
Brug, 1999^13^ | Diet, exercise, physical activity (not obesity) | 1 | 0 | 0 | | 1 | 2
Campbell, 1994^14^ | Diet, exercise, physical activity (not obesity) | 1 | 0 | 0 | | −1 | 0
Campbell, 1999^15^ | Diet, exercise, physical activity (not obesity) | 1 | 0 | 0 | | 1 | 2
Campbell, 2004^16^ | Diet, exercise, physical activity (not obesity) | 1 | 1 | 0 | | −1 | 1
Haerens, 2005^17^ | Diet, exercise, physical activity (not obesity) | 1 | 1 | 0 | | −1 | 1
Haerens, 2007^18^ | Diet, exercise, physical activity (not obesity) | 1 | 1 | −1 | | −1 | 0
Haerens, 2009^19^ | Diet, exercise, physical activity (not obesity) | 1 | 1 | 0 | | −1 | 1
Hurling, 2006^20^ | Diet, exercise, physical activity (not obesity) | 1 | 1 | 0 | | −1 | 1
Hurling, 2007^21^ | Diet, exercise, physical activity (not obesity) | 1 | 1 | | | 0 | 2
Jones, 2008^22^ | Diet, exercise, physical activity (not obesity) | 1 | 0 | 0 | −1 | 1 | 1
King, 2006^23^ | Diet, exercise, physical activity (not obesity) | 1 | 1 | 0 | | −1 | 1
Kristal, 2000^24^ | Diet, exercise, physical activity (not obesity) | 1 | 1 | 0 | | 1 | 3
Low, 2006^25^ | Diet, exercise, physical activity (not obesity) | 1 | 1 | | | 0 | 2
Lewis, 2008^26^ | Diet, exercise, physical activity (not obesity) | 1 | 1 | 0 | | 1 | 3
Marcus, 2007^27^ | Diet, exercise, physical activity (not obesity) | 1 | 1 | | | 1 | 3
Mangunkusumo, 2007^28^ | Diet, exercise, physical activity (not obesity) | 1 | | | | 0 | 1
Napolitano, 2003^29^ | Diet, exercise, physical activity (not obesity) | 1 | | −1 | | 0 | 0
Oenema, 2001^30^ | Diet, exercise, physical activity (not obesity) | 1 | 1 | −1 | | −1 | 0
Richardson, 2007^31^ | Diet, exercise, physical activity (not obesity) | 1 | 0 | 0 | | 1 | 2
Silk, 2008^32^ | Diet, exercise, physical activity (not obesity) | 1 | | | | −1 | 0
Smeets, 2007^33^ | Diet, exercise, physical activity (not obesity) | 1 | −1 | | | −1 | −1
Spittaels, 2007^34^ | Diet, exercise, physical activity (not obesity) | 1 | | −1 | | 1 | 1
Spittaels, 2007^35^ | Diet, exercise, physical activity (not obesity) | 1 | 0 | 0 | | 1 | 2
Tate, 2006^36^ | Diet, exercise, physical activity (not obesity) | 1 | 1 | 1 | 1 | 0 | 4
Vandelanotte, 2005^37^ | Diet, exercise, physical activity (not obesity) | 1 | | | | 0 | 1
Verheijden, 2004^38^ | Diet, exercise, physical activity (not obesity) | 1 | 0 | −1 | | 0 | 0
Winzelberg, 2000^39^ | Diet, exercise, physical activity (not obesity) | 1 | | | | −1 | 0
Wylie-Rosett, 2001^40^ | Diet, exercise, physical activity (not obesity) | 1 | 0 | 0 | | −1 | 0
Cunningham, 2005^41^ | Alcohol | 1 | | −1 | | 1 | 1
Hester, 2005^42^ | Alcohol | 1 | 1 | −1 | | 1 | 2
Kypri, 1999^43^ | Alcohol | 1 | 1 | 1 | 1 | 0 | 4
Lieberman, 2006^44^ | Alcohol | 1 | | −1 | | −1 | −1
Neighbors, 2004^45^ | Alcohol | 1 | | | | 0 | 1
Riper, 2008^46^ | Alcohol | 1 | 1 | −1 | | 1 | 2
Riper, 2008^47^ | Alcohol | 1 | 0 | 0 | | 1 | 2
An, 2008^48^ | Smoking cessation | 1 | 1 | −1 | | 1 | 2
Brendryen, 2008 49 | Smoking cessation | 1 | 0 | 0 | | 1 | 2
Curry, 1995 50 | Smoking cessation | 1 | 0 | 0 | | −1 | 0
Dijkstra, 2005 51 | Smoking cessation | 1 | 0 | 0 | | −1 | 0
Hang, 2009 52 | Smoking cessation | 1 | 1 | 0 | | 1 | 3
Japuntich, 2006^53^ | Smoking cessation | 1 | | | | 1 | 2
Pattents, 2006^54^ | Smoking cessation | 1 | | | | 0 | 1
Prochaska, 1993 55 | Smoking cessation | 1 | 0 | 0 | | 1 | 2
Prokhorov, 2008 56 | Smoking cessation | 1 | 0 | 0 | | 1 | 2
Schiffmans, 2000^57^ | Smoking cessation | 1 | 1 | | | 1 | 3
Schumann, 2006^58^ | Smoking cessation | 1 | | −1 | | −1 | −1
Schumann, 2008^59^ | Smoking cessation | 1 | 1 | −1 | | 1 | 2
Severson, 2008^60^ | Smoking cessation | 1 | | | | 1 | 2
Strecher, 1994 61 Study 1 | Smoking cessation | 1 | 0 | 0 | | 1 | 2
Strecher, 2005^62^ | Smoking cessation | 1 | | −1 | | −1 | −1
Strecher, 2005 63 | Smoking cessation | 1 | 0 | 0 | | | 1
Strecher, 2006^64^ | Smoking cessation | 1 | | −1 | | 0 | 0
Strecher, 2008^65^ | Smoking cessation | 1 | −1 | −1 | | 0 | −1
Swartz, 2006^66^ | Smoking cessation | 1 | 1 | −1 | | 0 | 1
Booth, 2008^67^ | Obesity | 1 | | | | 0 | 1
Burnett, 1985^68^ | Obesity | −1 | | −1 | | −1 | −3
Cussler, 2008^69^ | Obesity | 1 | | | | 1 | 2
Frenn, 2005^70^ | Obesity | 1 | −1 | −1 | | 0 | −2
Hunter, 2008^71^ | Obesity | 1 | 1 | −1 | | 1 | 2
Kent, 1985^68^ | Obesity | −1 | | −1 | | −1 | −3
Kroeze, 2008 72 | Obesity | 1 | 1 | | | 1 | 3
McConnon, 2007^73^ | Obesity | 1 | 1 | −1 | | 0 | 1
Morgan, 2009^74^ | Obesity | 1 | 1 | | 0 | 1 | 3
Taylor, 1991^75^ | Obesity | 1 | | | | −1 | 0
Williamson, 2006^76^ | Obesity | 1 | 1 | −1 | | 1 | 2
Womble, 2004^77^ | Obesity | 1 | 0 | | | 1 | 2
Glasgow, 2003^78^ | Diabetes | 1 | | −1 | | 0 | 0
Homko, 2007^79^ | Diabetes | 1 | | −1 | | 1 | 1
McKay, 2001^80^ | Diabetes | 1 | 1 | | | 1 | 3
Richardson, 2007^31^ | Diabetes | 1 | 1 | −1 | | 1 | 2
Wangberg, 2006^81^ | Diabetes | 1 | | | | 1 | 2
Wise, 1986^82^ | Diabetes | 1 | 1 | 0 | | −1 | 1
Lorig, 2006^83^ | Diabetes, heart disease | 1 | | −1 | | 1 | 1
Chiauzzi, 2008^84^ | Mental health | 1 | 1 | −1 | | −1 | 0
Christensen, 2004^85^ | Mental health | 1 | 1 | −1 | | 1 | 2
Hasson, 2005^86^ | Mental health | 1 | 1 | −1 | | 1 | 2
Neil, 2009^87^ | Mental health | 1 | 0 | 0 | | 1 | 2
Proudfoot, 2004^88^ | Mental health | 1 | 1 | | | 1 | 3
Schneider, 2005^89^ | Mental health | 1 | −1 | | | 1 | 1
Warmerdam, 2008^90^ | Mental health | 1 | 1 | 0 | | 1 | 3
Zetterqvist, 2003^91^ | Mental health | 1 | 0 | 0 | | 1 | 2
Jan, 2007^3^ | Asthma | 1 | 0 | −1 | | 1 | 1
Joseph, 2007^92^ | Asthma | 1 | 1 | −1 | | 1 | 2
Krishna, 2003^4^ | Asthma | 1 | | 1 | | 1 | 3
Nguyen, 2008^93^ | COPD | 1 | 1 | −1 | | 1 | 2
Paperny, 1990^94^ | Adolescent risk behavior | 1 | 1 | | 0 | 1 | 3
Lorig, 2008^95^ | Arthritis | 1 | | −1 | | 1 | 1
Buhrman, 2004^96^ | Back pain | 1 | | | | 1 | 2
Oenema, 2008^97^ | Behavioral risk factors | 1 | 1 | 0 | | 1 | 3
Chewning, 1999^5^ | Contraception use | 1 | −1 | | | 0 | 0
Kukafka, 2002^98^ | Cardio-vascular disease | 1 | | −1 | | −1 | −1
Jones. 1999^8^ | Cancer, general | 1 | 1 | | | 1 | 3
Campbell, 1997^99^ | Cancer, general | 1 | −1 | | | −1 | −1
Brennan, 1995^100^ | Caregiver decision making | 1 | | | | 1 | 2
Yardley, 2007^101^ | Prevention of falls in the elderly | 1 | 1 | 1 | 1 | 1 | 5
Harari, 2008^102^ | Change in health behavior | 1 | 1 | −1 | | 0 | 1
Devineni, 2005^103^ | Headache | 1 | | | | 1 | 2
Flatley-Brennan, 1998^104^ | HIV/AIDS | 1 | | −1 | | 0 | 0
Schapira, 2007^105^ | Menopause/HRT | 1 | 1 | −1 | | 1 | 2
Rostom, 2002^106^ | Menopause/HRT | 1 | 1 | −1 | | −1 | 0
Key Question 1 c (relationship-centered outcomes)
Green, 2005^107^ | Breast cancer | 1 | | −1 | | −1 | −1
Gustafson, 2001^7^ | Breast cancer | 1 | | | | 0 | 1
Maslin, 1998^108^ | Breast cancer | 1 | | −1 | | −1 | −1
Gustafson, 2008^6^ | Breast cancer | 1 | 1 | | | 0 | 2
Brennan, 1995^100^ | Caregiver decision making | 1 | | | | 1 | 2
Flatley-Brennan, 1998^104^ | HIV/AIDS | 1 | | −1 | | 0 | 0
Sciamanna, 2005^109^ | Osteoarthritis | 1 | | −1 | | −1 | −1
Montgomery, 2007^110^ | Newborn delivery | 1 | 1 | | | 1 | 3
Key Question 1 d (clinical outcomes)
Gustafson, 2001^7^ | Breast cancer | 1 | | | | 0 | 1
Gustafson, 2008^6^ | Breast cancer | 1 | 1 | | | 0 | 2
Maslin, 1998^108^ | Breast cancer | 1 | | −1 | | −1 | −1
Homko, 2007^79^ | Diabetes | 1 | | −1 | | 1 | 1
Tjam, 2006^111^ | Diabetes | 1 | 1 | −1 | | 0 | 1
Wise, 1986 82 | Diabetes | 1 | 1 | 0 | | −1 | 1
Adachi, 2007^9^ | Diet, exercise, physical activity (not obesity) | 1 | −1 | | | 0 | 0
Hunter, 2008^71^ | Diet, exercise, physical activity (not obesity) | 1 | 1 | −1 | | 1 | 2
McConnon, 2007^73^ | Diet, exercise, physical activity (not obesity) | 1 | 1 | −1 | | 0 | 1
Tate, 2006^36^ | Diet, exercise, physical activity (not obesity) | 1 | 1 | 1 | 1 | 0 | 4
Williamson, 2006^76^ | Diet, exercise, physical activity (not obesity) | 1 | 1 | −1 | | 1 | 2
Christensen, 2004^85^ | Mental health | 1 | 1 | −1 | | 1 | 2
Hasson, 2005^86^ | Mental health | 1 | 1 | −1 | | 1 | 2
Kerr, 2008^112^ | Mental health | 1 | | | | 0 | 1
March, 2008^113^ | Mental health | 1 | 1 | −1 | | 1 | 2
Orbach, 2007^114^ | Mental health | 1 | 1 | −1 | | 0 | 1
Proudfoot, 2003^115^ | Mental health | 1 | 1 | | | 1 | 3
Spek, 2008^116^ | Mental health | 1 | | | | 1 | 2
Tarraga, 2006^117^ | Alzheimers | 1 | | −1 | | 0 | 0
Lorig, 2008^95^ | Arthritis | 1 | | −1 | | 1 | 1
Jan, 2007^3^ | Asthma | 1 | 0 | −1 | | 1 | 1
Buhrman, 2004^96^ | Back pain | 1 | | | | 1 | 2
Katz, 1997^118^ | Chronic adult aphasia | 1 | | −1 | | 1 | 1
Nguyen, 2008^93^ | COPD | 1 | 1 | −1 | | 1 | 2
Trautman, 2008^119^ | Headache | 1 | 1 | | | 1 | 3
Gustafson, 1999^120^ | HIV/AIDS | 1 | 1 | −1 | | 1 | 2
Morgan, 2009^74^ | Obesity | 1 | 1 | | 0 | 1 | 3
Borckardt, 2007^121^ | Pain | 1 | | | | −1 | 0
Key Question 1 e (economic outcomes)
Jones, 1999^8^ | Cancer | 1 | | −1 | | 1 | 1
Joseph, 2007^92^ | Asthma | 1 | 1 | −1 | | 1 | 2
McConnon, 2007^73^ | Obesity | 1 | 1 | −1 | | 0 | 1
Key Question 2 (Barriers)
Wangberg, 2008^81^ | Diabetes | 1 | | | | 1 | 2
Mangunkusumo, 2007^28^ | Diet, exercise | 1 | | | | 0 | 1

Reference List

1 Bartholomew LK, Gold RS, Parcel GS et al. Watch, Discover, Think, and Act: Evaluation of computer-assisted instruction to improve asthma self-management in inner-city children. 2000; 39(2–3):269–80.

2 Guendelman S, Meade K, Benson M, Chen YQ, Samuels S. Improving asthma outcomes and self-management behaviors of inner-city children: A randomized trial of the Health Buddy interactive device and an asthma diary. 2002; 156(2):114–20.

3 Jan RL, Wang JY, Huang MC, Tseng SM, Su HJ, Liu LF. An internet-based interactive telemonitoring system for improving childhood asthma outcomes in Taiwan. Telemed J E Health 2007; 13(3):257–68.

4 Krishna S, Francisco BD, Balas EA, Konig P, Graff GR, Madsen RW. Internet-enabled interactive multimedia asthma education program: a randomized trial. Pediatrics 2003; 111(3):503–10.

5 Chewning B, Mosena P, Wilson D et al. Evaluation of a computerized contraceptive decision aid for adolescent patients. Patient Educ Couns 1999; 38(3):227–39.

6 Gustafson DH, Hawkins R, Mctavish F et al. Internet-based interactive support for cancer patients: Are integrated systems better? 2008; 58(2):238–57.

7 Gustafson DH, Hawkins R, Pingree S et al. Effect of computer support on younger women with breast cancer. J Gen Intern Med 2001; 16(7):435–45.

8 Jones R, Pearson J, McGregor S et al. Randomised trial of personalised computer based information for cancer patients. BMJ 1999; 319(7219):1241–7.

9 Adachi Y, Sato C, Yamatsu K, Ito S, Adachi K, Yamagami T. A randomized controlled trial on the long-term effects of a 1-month behavioral weight control program assisted by computer tailored advice. Behav Res Ther 2007; 45(3):459–70.

10 Anderson ES, Winett RA, Wojcik JR, Winett SG, Bowden T. A computerized social cognitive intervention for nutrition behavior: Direct and mediated effects on fat, fiber, fruits, and vegetables, self-efficacy, and outcome expectations among food shoppers. 2001; 23(2):88–100.

11 Brug J, Steenhuis I, Van Assema P, De Vries H. The impact of a computer-tailored nutrition intervention. 1996; 25(3):236–42.

12 Brug J, Glanz K, Van Assema P, Kok G, Van Breukelen GJP. The Impact of Computer-Tailored Feedback and Iterative Feedback on Fat, Fruit, and Vegetable Intake. 1998; 25(4):517–31.

13 Brug J, Steenhuis I, Van Assema P, Glanz K, De Vries H. Computer-tailored nutrition education: Differences between two interventions. 1999; 14(2):249–56.

14 Campbell MK, DeVellis BM, Strecher VJ, Ammerman AS, DeVellis RF, Sandler RS. Improving dietary behavior: The effectiveness of tailored messages in primary care settings. 1994; 84(5):783–7.

15 Campbell MK, Honess-Morreale L, Farrell D, Carbone E, Brasure M. A tailored multimedia nutrition education pilot program for low-income women receiving food assistance. 1999; 14(2):257–67.

16 Campbell MK, Carbone E, Honess-Morreale L, Heisler-MacKinnon J, Demissie S, Farrell D. Randomized trial of a tailored nutrition education CD-ROM program for women receiving food assistance. 2004; 36(2):58–66.

17 Haerens L, De Bourdeaudhuij I, Maes L, Vereecken C, Brug J, Deforche B. The effects of a middle-school healthy eating intervention on adolescents' fat and fruit intake and soft drinks consumption. 2007; 10(5):443–9.

18 Haerens L, Deforche B, Maes L, Brug J, Vandelanotte C, De Bourdeaudhuij I. A computer-tailored dietary fat intake intervention for adolescents: results of a randomized controlled trial. Ann Behav Med 2007; 34(3):253–62.

19 Haerens L, Maes L, Vereecken C, De Henauw S, Moreno L, De Bourdeaudhuij I. Effectiveness of a computer tailored physical activity intervention in adolescents compared to a generic advice. Patient Educ Couns 2009.

20 Hurling R, Fairley BW, Dias MB. Internet-based exercise intervention systems: Are more interactive designs better? 2006; 21(6):757–72.

21 Hurling R, Catt M, Boni MD et al. Using internet and mobile phone technology to deliver an automated physical activity program: randomized controlled trial. J Med Internet Res 2007; 9(2):e7.

22 Jones M, Luce KH, Osborne MI et al. Randomized, controlled trial of an internet-facilitated intervention for reducing binge eating and overweight in adolescents. Pediatrics 2008; 121(3):453–62.

23 King DK, Estabrooks PA, Strycker LA, Toobert DJ, Bull SS, Glasgow RE. Outcomes of a multifaceted physical activity regimen as part of a diabetes self-management intervention. 2006; 31(2):128–37.

24 Kristal AR, Curry SJ, Shattuck AL, Feng Z, Li S. A randomized trial of a tailored, self-help dietary intervention: The puget sound eating patterns study. 2000; 31(4):380–9.

25 Low KG, Charanasomboon S, Lesser J et al. Effectiveness of a computer-based interactive eating disorders prevention program at long-term follow-up. Eat Disord 2006; 14(1):17–30.

26 Lewis B, Williams D, Dunsiger S et al. User attitudes towards physical activity websites in a randomized controlled trial. Prev Med 2008; 47(5):508–13.

27 Marcus BH, Lewis BA, Williams DM et al. A comparison of Internet and print-based physical activity interventions. Arch Intern Med 2007; 167(9):944–9.

28 Mangunkusumo R, Brug J, Duisterhout J, de Koning H, Raat H. Feasibility, acceptability, and quality of Internet-administered adolescent health promotion in a preventive-care setting. Health Educ Res 2007; 22(1):1–13.

29 Napolitano MA, Fotheringham M, Tate D et al. Evaluation of an internet-based physical activity intervention: a preliminary investigation. Ann Behav Med 2003; 25(2):92–9.

30 Oenema A, Brug J, Lechner L. Web-based tailored nutrition education: results of a randomized controlled trial. Health Educ Res 2001; 16(6):647–60.

31 Richardson CR, Mehari KS, McIntyre LG et al. A randomized trial comparing structured and lifestyle goals in an internet-mediated walking program for people with type 2 diabetes. Int J Behav Nutr Phys Act 2007; 4:59.

32 Silk KJ, Sherry J, Winn B, Keesecker N, Horodynski MA, Sayir A. Increasing nutrition literacy: testing the effectiveness of print, web site, and game modalities. J Nutr Educ Behav 2008; 40(1):3–10.

33 Smeets T, Kremers SP, Brug J, de Vries H. Effects of tailored feedback on multiple health behaviors. Ann Behav Med 2007; 33(2):117–23.

34 Spittaels H, De Bourdeaudhuij I, Brug J, Vandelanotte C. Effectiveness of an online computer-tailored physical activity intervention in a real-life setting. Health Educ Res 2007; 22(3):385–96.

35 Spittaels H, De Bourdeaudhuij I, Vandelanotte C. Evaluation of a website-delivered computer-tailored intervention for increasing physical activity in the general population. 2007; 44(3):209–17.

36 Tate DF, Jackvony EH, Wing RR. A randomized trial comparing human e-mail counseling, computer-automated tailored counseling, and no counseling in an Internet weight loss program. Arch Intern Med 2006; 166(15):1620–5.

37 Vandelanotte C, De Bourdeaudhuij I, Sallis JF, Spittaels H, Brug J. Efficacy of sequential or simultaneous interactive computer-tailored interventions for increasing physical activity and decreasing fat intake. Ann Behav Med 2005; 29(2):138–46.

38 Verheijden M, Bakx JC, Akkermans R et al. Web-based targeted nutrition counselling and social support for patients at increased cardiovascular risk in general practice: randomized controlled trial. J Med Internet Res 2004; 6(4):e44.

39 Winzelberg AJ, Eppstein D, Eldredge KL et al. Effectiveness of an Internet-based program for reducing risk factors for eating disorders. J Consult Clin Psychol 2000; 68(2):346–50.

40 Wylie-Rosett J, Swencionis C, Ginsberg M et al. Computerized weight loss intervention optimizes staff time: The clinical and cost results of a controlled clinical trial conducted in a managed care setting. 2001; 101(10):1155–62.

41 Cunningham JA, Humphreys K, Koski-Jannes A, Cordingley J. Internet and paper self-help materials for problem drinking: is there an additive effect? Addict Behav 2005; 30(8):1517–23.

42 Hester RK, Squires DD, Delaney HD. The Drinker's Check-up: 12-month outcomes of a controlled clinical trial of a stand-alone software program for problem drinkers. J Subst Abuse Treat 2005; 28(2):159–69.

43 Kypri K, Saunders JB, Williams SM et al. Web-based screening and brief intervention for hazardous drinking: a double-blind randomized controlled trial. Addiction 2004; 99(11):1410–7.

44 Lieberman DZ. Effects of a personified guide on adherence to an online program for alcohol abusers. Cyberpsychol Behav 2006; 9(5):603–7.

45 Neighbors C, Larimer ME, Lewis MA. Targeting misperceptions of descriptive drinking norms: efficacy of a computer-delivered personalized normative feedback intervention. J Consult Clin Psychol 2004; 72(3):434–47.

46 Riper H, Kramer J, Smit F, Conijn B, Schippers G, Cuijpers P. Web-based self-help for problem drinkers: a pragmatic randomized trial. Addiction 2008; 103(2):218–27.

47 Riper H, Kramer J, Keuken M, Smit F, Schippers G, Cuijpers P. Predicting successful treatment outcome of web-based self-help for problem drinkers: secondary analysis from a randomized controlled trial. J Med Internet Res 2008; 10(4):e46.

48 An LC, Klatt C, Perry CL et al. The RealU online cessation intervention for college smokers: a randomized controlled trial. Prev Med 2008; 47(2):194–9.

49 Brendryen H, Drozd F, Kraft P. A digital smoking cessation program delivered through internet and cell phone without nicotine replacement (happy ending): randomized controlled trial. J Med Internet Res 2008; 10(5):e51.

50 Curry SJ, McBride C, Grothaus LC, Louie D, Wagner EH. A randomized trial of self-help materials, personalized feedback, and telephone counseling with nonvolunteer smokers. 1995; 63(6):1005–14.

51 Dijkstra A. Working mechanisms of computer-tailored health education: Evidence from smoking cessation. 2005; 20(5):527–39.

52 Haug S, Meyer C, Schorr G, Bauer S, John U. Continuous individual support of smoking cessation using text messaging: A pilot experimental study. Nicotine Tob Res 2009.

53 Japuntich SJ, Zehner ME, Smith SS et al. Smoking cessation via the internet: a randomized clinical trial of an internet intervention as adjuvant treatment in a smoking cessation intervention. Nicotine Tob Res 2006; 8 Suppl 1:S59–67.

54 Patten CA, Croghan IT, Meis TM et al. Randomized clinical trial of an Internet-based versus brief office intervention for adolescent smoking cessation. Patient Educ Couns 2006; 64(1–3):249–58.

55 Prochaska JO, DiClemente CC, Velicer WF, Rossi JS. Standardized, Individualized, Interactive, and Personalized Self-Help Programs for Smoking Cessation. 1993; 12(5):399–405.

56 Prokhorov AV, Kelder SH, Shegog R et al. Impact of A Smoking Prevention Interactive Experience (ASPIRE), an interactive, multimedia smoking prevention and cessation curriculum for culturally diverse high-school students. Nicotine Tob Res 2008; 10(9):1477–85.

57 Shiffman S, Paty JA, Rohay JM, Di Marino ME, Gitchell J. The efficacy of computer-tailored smoking cessation material as a supplement to nicotine polacrilex gum therapy. Arch Intern Med 2000; 160(11):1675–81.

58 Schumann A, John U, Rumpf H-J, Hapke U, Meyer C. Changes in the "stages of change" as outcome measures of a smoking cessation intervention: A randomized controlled trial. 2006; 43(2):101–6.

59 Schumann A, John U, Baumeister SE, Ulbricht S, Rumpf HJ, Meyer C. Computer-tailored smoking cessation intervention in a general population setting in Germany: outcome of a randomized controlled trial. Nicotine Tob Res 2008; 10(2):371–9.

60 Severson HH, Gordon JS, Danaher BG, Akers L. ChewFree.com: evaluation of a Web-based cessation program for smokeless tobacco users. Nicotine Tob Res 2008; 10(2):381–91.

61 Strecher VJ, Kreuter M, Den Boer D-J, Kobrin S, Hospers HJ, Skinner CS. The effects of computer-tailored smoking cessation messages in family practice settings. 1994; 39(3):262–70.

62 Strecher VJ, Shiffman S, West R. Randomized controlled trial of a web-based computer-tailored smoking cessation program as a supplement to nicotine patch therapy. Addiction 2005; 100(5):682–8.

63 Strecher VJ, Marcus A, Bishop K et al. A randomized controlled trial of multiple tailored messages for smoking cessation among callers to the cancer information service. J Health Commun 2005; 10 Suppl 1:105–18.

64 Strecher VJ, Shiffman S, West R. Moderators and mediators of a web-based computer-tailored smoking cessation program among nicotine patch users. Nicotine Tob Res 2006; 8 Suppl 1:S95–101.

65 Strecher VJ, McClure JB, Alexander GL et al. Web-based smoking-cessation programs: results of a randomized trial. Am J Prev Med 2008; 34(5):373–81.

66 Swartz LH, Noell JW, Schroeder SW, Ary DV. A randomised control study of a fully automated internet based smoking cessation programme. Tob Control 2006; 15(1):7–12.

67 Booth AO, Nowson CA, Matters H. Evaluation of an interactive, Internet-based weight loss program: a pilot study. Health Educ Res 2008; 23(3):371–81.

68 Burnett KF, Taylor CB, Agras WS. Ambulatory computer-assisted therapy for obesity: A new frontier for behavior therapy. 1985; 53(5):698–703.

69 Cussler EC, Teixeira PJ, Going SB et al. Maintenance of weight loss in overweight middle-aged women through the Internet. Obesity (Silver Spring) 2008; 16(5):1052–60.

70 Frenn M, Malin S, Brown RL et al. Changing the tide: An Internet/video exercise and low-fat diet intervention with middle-school students. 2005; 18(1):13–21.

71 Hunter CM, Peterson AL, Alvarez LM et al. Weight management using the internet a randomized controlled trial. Am J Prev Med 2008; 34(2):119–26.

72 Kroeze W, Oenema A, Campbell M, Brug J. The efficacy of Web-based and print-delivered computer-tailored interventions to reduce fat intake: results of a randomized, controlled trial. J Nutr Educ Behav 2008; 40(4):226–36.

73 McConnon A, Kirk SF, Cockroft JE et al. The Internet for weight control in an obese sample: results of a randomised controlled trial. BMC Health Serv Res 2007; 7:206.

74 Morgan PJ, Lubans DR, Collins CE, Warren JM, Callister R. The SHED-IT Randomized Controlled Trial: Evaluation of an Internet-based Weight-loss Program for Men. Obesity (Silver Spring) 2009.

75 Taylor CB, Agras WS, Losch M, Plante TG, Burnett K. Improving the effectiveness of computer-assisted weight loss. 1991; 22(2):229–36.

76 Williamson DA, Walden HM, White MA et al. Two-year internet-based randomized controlled trial for weight loss in African-American girls. Obesity (Silver Spring) 2006; 14(7):1231–43.

77 Womble LG, Wadden TA, McGuckin BG, Sargent SL, Rothman RA, Krauthamer-Ewing ES. A randomized controlled trial of a commercial internet weight loss program. Obes Res 2004; 12(6):1011–8.

78 Glasgow RE, Boles SM, McKay HG, Feil EG, Barrera M Jr. The D-Net diabetes self-management program: long-term implementation, outcomes, and generalization results. Prev Med 2003; 36(4):410–9.

79 Homko CJ, Santamore WP, Whiteman V et al. Use of an internet-based telemedicine system to manage underserved women with gestational diabetes mellitus. Diabetes Technol Ther 2007; 9(3):297–306.

80 McKay HG, King D, Eakin EG, Seeley JR, Glasgow RE. The diabetes network internet-based physical activity intervention: a randomized pilot study. Diabetes Care 2001; 24(8):1328–34.

81 Wangberg SC. An Internet-based diabetes self-care intervention tailored to self-efficacy. Health Educ Res 2008; 23(1):170–9.

82 Wise PH, Dowlatshahi DC, Farrant S. Effect of computer-based learning on diabetes knowledge and control. 1986; 9(5):504–8.

83 Lorig KR, Ritter PL, Laurent DD, Plant K. Internet-based chronic disease self-management: a randomized trial. Med Care 2006; 44(11):964–71.

84 Chiauzzi E, Brevard J, Thurn C, Decembrele S, Lord S. MyStudentBody-Stress: an online stress management intervention for college students. J Health Commun 2008; 13(6):555–72.

85 Christensen H, Griffiths KM, Jorm AF. Delivering interventions for depression by using the internet: randomised controlled trial. BMJ 2004; 328(7434):265.

86 Hasson D, Anderberg UM, Theorell T, Arnetz BB. Psychophysiological effects of a web-based stress management system: a prospective, randomized controlled intervention study of IT and media workers. BMC Public Health 2005; 5:78.

87 Neil AL, Batterham P, Christensen H, Bennett K, Griffiths KM. Predictors of adherence by adolescents to a cognitive behavior therapy website in school and community-based settings. J Med Internet Res 2009; 11(1):e6.

88 Proudfoot J, Ryden C, Everitt B et al. Clinical efficacy of computerised cognitive-behavioural therapy for anxiety and depression in primary care: randomised controlled trial. Br J Psychiatry 2004; 185:46–54.

89 Schneider AJ, Mataix-Cols D, Marks IM, Bachofen M. Internet-guided self-help with or without exposure therapy for phobic and panic disorders. Psychother Psychosom 2005; 74(3):154–64.

90 Warmerdam L, van Straten A, Twisk J, Riper H, Cuijpers P. Internet-based treatment for adults with depressive symptoms: randomized controlled trial. J Med Internet Res 2008; 10(4):e44.

91 Zetterqvist K, Maanmies J, Str+¦m L, Andersson G. Randomized controlled trial of internet-based stress management. 2003; 32(3):151–60.

92 Joseph CL, Peterson E, Havstad S et al. A web-based, tailored asthma management program for urban African-American high school students. Am J Respir Crit Care Med 2007; 175(9):888–95.

93 Nguyen HQ, Donesky-Cuenco D, Wolpin S et al. Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res 2008; 10(2):e9.

94 Paperny DM, Aono JY, Lehman RM, Hammar SL, Risser J. Computer-assisted detection and intervention in adolescent high-risk health behaviors. 1990; 116(3):456–62.

95 Lorig KR, Ritter PL, Laurent DD, Plant K. The internet-based arthritis self-management program: a one-year randomized trial for patients with arthritis or fibromyalgia. Arthritis Rheum 2008; 59(7):1009–17.

96 Buhrman M, Faltenhag S, Strom L, Andersson G. Controlled trial of Internet-based treatment with telephone support for chronic back pain. Pain 2004; 111(3):368–77.

97 Oenema A, Brug J, Dijkstra A, de Weerdt I, de Vries H. Efficacy and use of an internet-delivered computer-tailored lifestyle intervention, targeting saturated fat intake, physical activity and smoking cessation: a randomized controlled trial. Ann Behav Med 2008; 35(2):125–35.

98 Kukafka R, Lussier YA, Eng P, Patel VL, Cimino JJ. Web-based tailoring and its effect on self-efficacy: results from the MI-HEART randomized controlled trial. Proc AMIA Symp 2002; 410–4.

99 Campbell E, Peterkin D, Abbott R, Rogers J. Encouraging underscreened women to have cervical cancer screening: the effectiveness of a computer strategy. Prev Med 1997; 26(6):801–7.

100 Brennan PF, Moore SM, Smyth KA. The effects of a special computer network on caregivers of persons with Alzheimer's disease. Nurs Res 1995; 44(3):166–72.

101 Yardley L, Nyman SR. Internet provision of tailored advice on falls prevention activities for older people: a randomized controlled evaluation. Health Promot Int 2007; 22(2):122–8.

102 Harari D, Iliffe S, Kharicha K et al. Promotion of health in older people: a randomised controlled trial of health risk appraisal in British general practice. Age Ageing 2008; 37(5):565–71.

103 Devineni T, Blanchard EB. A randomized controlled trial of an internet-based treatment for chronic headache. Behav Res Ther 2005; 43(3):277–92.

104 Flatley-Brennan P. Computer network home care demonstration: a randomized trial in persons living with AIDS. Comput Biol Med 1998; 28(5):489–508.

105 Schapira MM, Gilligan MA, McAuliffe T, Garmon G, Carnes M, Nattinger AB. Decision-making at menopause: a randomized controlled trial of a computer-based hormone therapy decision-aid. Patient Educ Couns 2007; 67(1–2):100–7.

106 Rostom A, O'Connor A, Tugwell P, Wells G. A randomized trial of a computerized versus an audio-booklet decision aid for women considering post-menopausal hormone replacement therapy. Patient Educ Couns 2002; 46(1):67–74.

107 Green MJ, Peterson SK, Baker MW et al. Use of an educational computer program before genetic counseling for breast cancer susceptibility: effects on duration and content of counseling sessions. Genet Med 2005; 7(4):221–9.

108 Maslin AM, Baum M, Walker JS, A'Hern R, Prouse A. Using an interactive video disk in breast cancer patient support. Nurs Times 1998; 94(44):52–5.

109 Sciamanna CN, Harrold LR, Manocchia M, Walker NJ, Mui S. The effect of web-based, personalized, osteoarthritis quality improvement feedback on patient satisfaction with osteoarthritis care. Am J Med Qual 2005; 20(3):127–37.

110 Montgomery AA, Emmett CL, Fahey T et al. Two decision aids for mode of delivery among women with previous caesarean section: randomised controlled trial. BMJ 2007; 334(7607):1305.

111 Tjam EY, Sherifali D, Steinacher N, Hett S. Physiological outcomes of an internet disease management program vs. in-person counselling: A randomized, controlled trial. 2006; 30(4):397–405.

112 Kerr J, Patrick K, Norman G et al. Randomized control trial of a behavioral intervention for overweight women: impact on depressive symptoms. Depress Anxiety 2008; 25(7):555–8.

113 March S, Spence SH, Donovan CL. The Efficacy of an Internet-Based Cognitive-Behavioral Therapy Intervention for Child Anxiety Disorders. J Pediatr Psychol 2008.

114 Orbach G, Lindsay S, Grey S. A randomised placebo-controlled trial of a self-help Internet-based intervention for test anxiety. Behav Res Ther 2007; 45(3):483–96.

115 Proudfoot J, Goldberg D, Mann A, Everitt B, Marks I, Gray JA. Computerized, interactive, multimedia cognitive-behavioural program for anxiety and depression in general practice. Psychol Med 2003; 33(2):217–27.

116 Spek V, Cuijpers P, Nyklicek I et al. One-year follow-up results of a randomized controlled clinical trial on internet-based cognitive behavioural therapy for subthreshold depression in people over 50 years. Psychol Med 2008; 38(5):635–9.

117 Tarraga L, Boada M, Modinos G et al. A randomised pilot study to assess the efficacy of an interactive, multimedia tool of cognitive stimulation in Alzheimer's disease. J Neurol Neurosurg Psychiatry 2006; 77(10):1116–21.

118 Katz RC, Wertz RT. The efficacy of computer-provided reading treatment for chronic aphasic adults. J Speech Lang Hear Res 1997; 40(3):493–507.

119 Trautmann E, Kro?ner-Herwig B. Internet-based self-help training for children and adolescents with recurrent headache: A pilot study. 2008; 36(2):241–5.

120 Gustafson DH, Hawkins R, Boberg E et al. Impact of a patient-centered, computer-based health information/support system. Am J Prev Med 1999; 16(1):1–9.

121 Borckardt JJ, Younger J, Winkel J, Nash MR, Shaw D. The computer-assisted cognitive/imagery system for use in the management of pain. Pain Res Manag 2004; 9(3):157–62.

Evidence Table 2

Description of RCTs addressing the impact of CHI applications on health care processes (KQ1a)

Author, year | Consumer under study | CHI Application type | Location | Year data collected/ duration of intervention | Inclusion criteria | Exclusion criteria | Control | Intervention | Jadad score
Asthma
Bartholomew, 2000 1 | Inner-city elementary and middle school–age 6–17 children with moderate to severe asthma | Watch, Discover, Think and Act (An Interactive multimedia application on CD-ROM) | Physician office | 4 to 15.6 | Age 6–17 years, Moderate-to-severe asthma, English speaking parents, No chronic disease other than asthma | Not speaking English, co-existing disease, inadequate reading level, parent inability to understand the study | Participant assigned to usual-care | Participant assigned to Watch, Discover, Think and Act
Guendelman, 2002 2 | Inner-city children as having asthma by a physician. | Personal and interactive communication device (Health Buddy | Home and in an outpatient hospital clinic. | April 8, 1999, and July 5, 2000 | Children age 8–16 years, had an English- speaking caregiver, had a telephone at home, and were diagnosed as having persistent asthma, Patient with 2 or more emergency department (ED) visits and/or at least 1 inpatient admission during the year before the study | Patients involved in other asthma or drug efficacy studies, Involved in research that required behavior modification, Mental or physical challenges that made difficult to use Health Buddy. Children with co- morbid conditions that could affect their quality of life. | Participants using asthma diary | Participants using Health Buddy
Jan, 2007^3^ | Individuals interested in their own health care Caregiver, childhood asthma | Personal monitoring device | Home/ residence | 2004/ January to December | 6 – 12 yr, Caregivers have Internet access, persistent asthma diagnosis (GINA clinical practice guidelines) | Diagnosed with Bronchopulmonary dysplasia, Diagnosed with other chronic co morbid conditions that could affect quality of life | Verbal information and booklet for asthma education with written asthma diary. | Blue Angel for Asthma Kids An Internet-based diary record for peak expiratory flow rate (PEFR) Symptomatic support information, and an action plan suggestion, and telecommunication technologies for uploading and retrieving the storage data | 1
Krishna, 2003^4^ | Individuals interested in their own health Parents/caregivers | Personal monitoring device | Home/ residence | 1999/ NS | < 18 yr, Confirmed asthma | Cystic fibrosis, Bronchopulmonary dysplasia, Other chronic lung disease | Traditional care | Internet-enabled interactive multimedia asthma education program | 3
Use of Contraception
Chewining, 1999^5^ | Individuals interested in their own health care | Computer- Based Decision Aid | Clinician office | NS | ≤ 20 yr, Female, ability to read and understand English, Expressed interest in getting a contraceptive | | Standard information | Computer- Based Interactive Decision Aid | 0

Yr = Year, NS = not specified, PEFR = Peak expiratory flow rate

Reference List

1 Bartholomew LK, Gold RS, Parcel GS et al. Watch, Discover, Think, and Act: Evaluation of computer-assisted instruction to improve asthma self-management in inner-city children. 2000; 39(2–3):269–80.

2 Guendelman S, Meade K, Benson M, Chen YQ, Samuels S. Improving asthma outcomes and self-management behaviors of inner-city children: A randomized trial of the Health Buddy interactive device and an asthma diary. 2002; 156(2):114–20.

3 Jan RL, Wang JY, Huang MC, Tseng SM, Su HJ, Liu LF. An internet-based interactive telemonitoring system for improving childhood asthma outcomes in Taiwan. Telemed J E Health 2007; 13(3):257–68.

4 Krishna S, Francisco BD, Balas EA, Konig P, Graff GR, Madsen RW. Internet-enabled interactive multimedia asthma education program: a randomized trial. Pediatrics 2003; 111(3):503–10.

5 Chewning B, Mosena P, Wilson D et al. Evaluation of a computerized contraceptive decision aid for adolescent patients. Patient Educ Couns 1999; 38(3):227–39.

Evidence Table 3

Description of consumer characteristics in RCTs addressing the impact of CHI applications on health care processes (KQ1a)

Author, Year | Control Intervention | Age | Race, n(%) | Income | Education, n(%) | SES | Gender, n(%) | Other characteristics
Asthma
Bartholomew, 2000^1^ | Control n=63 usual care | Range, 6–17 | Hispanic,28(44.1) African American,32(50.8) White ,3(4.8) Other, | NS | Parent education: None, 2(3.2) Elementary, 15(23.8) High school, 28(44.4) College, 18(27.0) | NS | Male, 44(69.8) Female, 19(30.2) | Insurance (private) ,5(8.5) Medicare, 5(8.5) Medicate, 27(45.8) Self pay, 3(5.1) None, 19(32.2) Asthma: Mild, 13(24.6) Moderate, 25(47.2) Severe, 15(28.3) Parent’s marital status: Single, 15(23.8) Married, 39(61.9) Widowed, 2(3.2) Divorced, 3(4.8) Separated, 4(6.3) Parent in home: One, 24(38.1) Two, 39(61.9) Parents employment : Fulltime , 30(48.4) Part-time, 8(12.9) Not, 24(38.7) Parents education: None,2(3.2) 15(23.8) High school, 28(44.4) College, 18(27.0)
Bartholomew, 2000^1^ | Intervention n,70 computer intervention (watch, discover, think and act) | Range,6–17 | Hispanic,33(47.1) African American,34(48.6) White ,2(2.9) Other,1(1.4) | NS | None,3(4.3) Elementary, 20(29.0) High school, 34(49.3) College, 12(17.3) | NS | Male, 42(60.0) Female, 28(40.0) | Insurance (private), 3(5.1) Medicare, 3(5.1) Medicate, 30(50.8) Self pay, 5(8.5) None, 18(30.5) Asthma: Mild, 22(40.8) Moderate, 14(25.9) Severe, 18(33.3) Parent’s marital status: Single, 15(21.7) Married, 39(56.5) Widowed, 1(1.4) Divorced, 4(5.8) Separated, 10(14.5) Parent in home: One, 30(44.1) Two, 38(55.9) Parents employment : Fulltime , 18(27.3) Part-time, 12(18.2) Not, 36(54.5) Parents education: None, 3(4.3) Elementary, 20(29.0) High school, 34(49.3) College, 12(17.3)
Guendelman, 2002^2^ | Control, 68 participants used an asthma diary. | 12.2 (2.9) | Black, 50 (74) White, 8 (12) Others, 10 (15) | N | NS | NS | Male, 37 (54 | Public health insurance,63(93) Private health insurance,4(6) Parent is the care-giver ,55(81) Primary caregiver education - high school,35(51) College,33(49) Passive smoking in the household,36(53) Mild asthma,20(29) Moderate asthma,40(59) Severe asthma ,8(12) Daily puffs of quick-relief medication,15(0.7) ER visit,2.40(2.33) Nights in the hospital,0.66(1.23)
Guendelman, 2002^2^ | Intervention,66 Health Buddy(is a personal and interactive communication device) | 12.0 (2.3 | Black, 52 (79) White,5 (8) Others,9 (14) | NS | NS | NS | Male, 40 (61) | Public health insurance,61(92) Private health insurance,5(8) Parent is the care-giver ,47(71) Primary caregiver education high school,26(39) College,40(61) Passive smoking in the household,35(53) Mild asthma,15(23) Moderate asthma,43(66) Severe asthma ,7(11) Daily puffs of quick-relief medication,1.6(0.7) ER visit ,2.10(2.09) Nights in the hospital,0.56(1.04)
Jan, 2007^3^ | Verbal information and booklet for asthma education with written asthma diary | Mean, 9.9 SD, 3.2 | NR | NR | Education of primary caregiver HS diploma or below, 43(56.6) College or above, 33(43.4) | NR | M, 28(36.8) F, 48(63.2) | History of asthma (yr), mean, 2.1 SD, 1.2 Asthma severity: mild, 33(43.4) moderate, 35(46.1) severe, 8(10.5)
Jan, 2007^3^ | Intervention | Mean, 10.9 SD, 2.5 | NR | NR | Education of primary caregiver HS diploma or below, 58(66.0) College or above, 30(34.0) | NR | M, 35(39.7) F, 53(60.2) | History of asthma (yr), mean, 2.4 SD, 1.9 Asthma severity: mild, 33(37.5) moderate, 43(48.9) severe, 12(13.6)
Krishna, 2003^4^ | Traditional care | Range, 0-17 | White non-Hispanic, 102(84.3) Black non-Hispanic, 9(7.4) AIAN, 7(5.8) Not specified, 3 | NR | Preschool/none, 58(47.9) Kindergarten, 6(5) Elementary, 27(22.3) Jr High, 24(19.8) High School, 6(5) | NR | M, 76(62.8) F, 45(37.2)
Krishna, 2003^4^ | Internet-enabled interactive Multimedia asthma education program | Range, 0–17 | White non-Hispanic, 93(86.9) Black non-Hispanic, 10(9.3) AIAN, 2(1.9) Not specified, 2(1.9) | NR | Preschool/none, 48(44.9) Kindergarten, 12(11.2) Elementary, 23(21.5) Jr High, 19(17.6) High school, 5(4.1) | NR | M, 72(67.3) F, 35(32.7)
Use of contraception
Chewning, 1999^5^ | Standard information | NR | NR | NR | NR | NR | F(100) | NR
Chewning, 1999^5^ | Computerized decision aid | NR | NR | NR | NR | NR | F(100) | NR

NR= Not Reported, SD= Standard Deviation, SES= Socioeconomic Status, Yr= year, CBT= Cognitive Behavioral Therapy, WL= Wait List, AIAN= American Indian/Alaska Native, M = Male, F = Female

Reference List

1 Bartholomew LK, Gold RS, Parcel GS et al. Watch, Discover, Think, and Act: Evaluation of computer-assisted instruction to improve asthma self-management in inner-city children. 2000; 39(2–3):269–80.

2 Guendelman S, Meade K, Benson M, Chen YQ, Samuels S. Improving asthma outcomes and self-management behaviors of inner-city children: A randomized trial of the Health Buddy interactive device and an asthma diary. 2002; 156(2):114–20.

3 Jan RL, Wang JY, Huang MC, Tseng SM, Su HJ, Liu LF. An internet-based interactive telemonitoring system for improving childhood asthma outcomes in Taiwan. Telemed J E Health 2007; 13(3):257–68.

4 Krishna S, Francisco BD, Balas EA, Konig P, Graff GR, Madsen RW. Internet-enabled interactive multimedia asthma education program: a randomized trial. Pediatrics 2003; 111(3):503–10.

5 Chewning B, Mosena P, Wilson D et al. Evaluation of a computerized contraceptive decision aid for adolescent patients. Patient Educ Couns 1999; 38(3):227–39.

Evidence table 4

Outcomes in studies addressing Key Question 1a, impact of CHI applications on health care processes

Author, Year | Outcome | Control Intervention | n | Measure at BL | Measure at final time point | ratios at time points | Significance
Asthma
Bartholomew, 2000^1^ | | Control: Usual care | 63
Bartholomew, 2000^1^ | | Intervention Watch, Discover, Think and Act (An Interactive multimedia application on CD-ROM) | 70
Guendelman, 2002^2^ | Health and quality of life and process evaluation | Control: participants used an asthma diary | 66 | Limitation in activity No:19 (28) Yes: 49 (72) Peak flow measurement ever: No 12 (18) Yes 20 (29) Missing data: 36 (53) Coughing No7(10) Yes 61(90) Trouble sleeping No Yes | Limitation in activity No:32 (53) Yes: 28(47) Peak flow measurement No 27(40) Yes 26 (38) Missing data 36 (53) Coughing No21(35) Yes39(65) Trouble sleeping No Yes | | .03
Guendelman, 2002^2^ | Health and quality of life and process evaluation | Intervention: Health Buddy(is a personal and interactive communication device) | 68 | Limitation in activity No: 22 (33) Yes:44 (67) Peak flow measurement ever No 14 (21) Yes 22(33) Missing data 30 (45) Coughing No10(15) Yes56(85) Trouble sleeping No Yes | Limitation in activity No: 42 (68) Yes:20(32) Peak flow measurement ever No 38 (58) Yes 19(29) Missing data 09 (14) Coughing No23(37) Yes39(63) Trouble sleeping No Yes | 0.52 | .03
Jan, 2007^3^ | Monitoring adherence | Control | 71 | Mean, 85.6 | 12 week mean, 93.5
Jan, 2007^3^ | Monitoring adherence | Asthma education and an interactive asthma monitoring system | 82 | Mean, 83.5 | 12 week mean, 99.7
Jan, 2007^3^ | Therapeutic adherence | Control | 15
Jan, 2007^3^ | Therapeutic adherence | Asthma education and an interactive asthma monitoring system | 23
Jan, 2007^3^ | Adherence to daily diary entry | Control | 71 | Mean, 93.2 | 12 week mean, 53.4
Jan, 2007^3^ | Adherence to daily diary entry | Asthma education and an interactive asthma monitoring system | 82 | Mean, 96 | 12 week mean, 82.5
Jan, 2007^3^ | Therapeutic adherence: DPI or MDI plus spacer technique score | Control | 71 | Mean, 80.3 | 12 week mean, 93.4
Jan, 2007^3^ | Therapeutic adherence: DPI or MDI plus spacer technique score | Asthma education and an interactive asthma monitoring system | 82 | Mean, 82.1 | 12 week mean, 96.5
Jan, 2007^3^ | Peak flow meter technique score | Control | 97 | Mean, 82.3 | 12 week mean, 42.1
Jan, 2007^3^ | Peak flow meter technique score | Asthma education and an interactive asthma monitoring system | 99 | Mean, 83.5 | 12 week mean, 63.2
Krishna, 2003^4^ | Days of quick relief medicine | Control | 44 | Mean, 90.7 SD, 114.8 | 12 months mean, 41 SD, 82
Krishna, 2003^4^ | Days of quick relief medicine | Internet-enabled asthma education program | 42 | | 12 months mean, 26.3 SD, 56.6
Krishna, 2003^4^ | Urgent physician visit | Control | 44 | Mean, 6.4 SD, 10.5 | 12 months mean, 1.3 SD, 2.2
Krishna, 2003^4^ | Urgent physician visit | Internet-enabled asthma education program | 42 | Mean, 6.6 SD, 10.5 | 12 months mean, 0.8 SD, 1.5
Krishna, 2003^4^ | Emergency room visit | Control | 44 | Mean, 1.2 SD, 2.8 | 12 months mean, 0.6 SD, 1.1
Krishna, 2003^4^ | Emergency room visit | Internet-enabled asthma education program | 42 | Mean, 2 SD, 4.2 | 12 months mean, 0.1 SD, 0.4
Krishna, 2003^4^ | Daily dose of inhaled corticosteroids | Control | 44 | Mean, 350.53 SD, 649.61 | 12 months mean, 753.88 SD, 706.94
Krishna, 2003^4^ | Daily dose of inhaled corticosteroids | Internet-enabled asthma education program | 42 | Mean, 353.09 SD, 615.83 | 12 months mean, 433.51 SD, 569.13
Use of contraception
Chewning, 1999^5^ | Oral contraceptive efficacy Chicago | Control | NA | Initial visit mean, 11.26 SD, 15.93 | 1 yr mean, 6.38 SD, 13.45 | | NS
Chewning, 1999^5^ | Oral contraceptive efficacy Chicago | Computerized decision aid | NA | Initial visit mean, 4.59 SD, 9.2 | 1 yr mean, 5.66 SD, 8.45 | | NS
Chewning, 1999^5^ | Oral contraceptive efficacy Madison | Control | NA | Initial visit mean, 4.8 SD, 5.58 | 1 yr mean, 4.83 SD, 9.15 | | NS
Chewning, 1999^5^ | Oral contraceptive efficacy Madison | Computerized decision aid | NA | Initial visit mean, 2.09 SD, 2.2 | 1 yr mean, 4 SD, 8.26 | | NS

NA= Not applicable, NS= Not Significant, Yr = year, BL = baseline, SD = standard deviation

Reference List

1 Bartholomew LK, Gold RS, Parcel GS et al. Watch, Discover, Think, and Act: Evaluation of computer-assisted instruction to improve asthma self-management in inner-city children. 2000; 39(2–3):269–80.

2 Guendelman S, Meade K, Benson M, Chen YQ, Samuels S. Improving asthma outcomes and self-management behaviors of inner-city children: A randomized trial of the Health Buddy interactive device and an asthma diary. 2002; 156(2):114–20.

3 Jan RL, Wang JY, Huang MC, Tseng SM, Su HJ, Liu LF. An internet-based interactive telemonitoring system for improving childhood asthma outcomes in Taiwan. Telemed J E Health 2007; 13(3):257–68.

4 Krishna S, Francisco BD, Balas EA, Konig P, Graff GR, Madsen RW. Internet-enabled interactive multimedia asthma education program: a randomized trial. Pediatrics 2003; 111(3):503–10.

5 Chewning B, Mosena P, Wilson D et al. Evaluation of a computerized contraceptive decision aid for adolescent patients. Patient Educ Couns 1999; 38(3):227–39.

Evidence Table 5

Description of RCTs addressing KQ1b (impact of CHI applications on intermediate outcomes)

Author, year | Consumer under study | CHI Application type | Location | Year data collected/duration of intervention | Inclusion criteria | Exclusion criteria | Control | Intervention | Jadad score
Breast cancer
Gustafson, 2001^1^ | Individuals interested in their own health care | Interactive consumer computer-based program | Home/residence | Accrued between April 1995 and May 1997 | <60 yr, Women within 6 months of diagnosis of breast cancer, Not homeless, able to give informed consent, Understand and answer sample questions from the pretest Not active illegal drug users | | Given copy of Dr. Susan Love’s Breast Book | CHESS intervention on home computer connecting to central server | 1
Gustafson, 2008^2^ | Individuals interested in their own health care | Interactive consumer website | Home/residence | NS | Women within 61 days of breast cancer diagnosis. Not homeless, able to give informed consent, understand and answer sample questions from the pretest | | 1.Choice of several books on breast cancer or set of audiotapeOR 2. Access to the Internet | CHESS interactive website, General website and the Internet | 2
Breast cervical prostate and laryngeal cancer
Jones, 1999^3^ | Individual interested in their own health care | Interactive consumer website | Clinician office | 1996–1997 patients identified | Existing breast, cervical, prostate, or laryngeal, cancer patients receiving radiotherapy at one oncology center | Receiving palliative treatment, No knowledge of diagnosis, visual or mental handicap, severe pain or symptoms | 1. Booklet information-2. General information about cancer, organized on computer as hypertext document | Personalized information-summary of their medical record & hypertext links to terms. Access to general system menu | 1

Yr = year, CHESS = Comprehensive Health Enhancement Support System, NS = Not specified

Reference List

1 Gustafson DH, Hawkins R, Pingree S et al. Effect of computer support on younger women with breast cancer. J Gen Intern Med 2001; 16(7):435–45.

2 Gustafson DH, Hawkins R, Mctavish F et al. Internet-based interactive support for cancer patients: Are integrated systems better? 2008; 58(2):238–57.

3 Jones R, Pearson J, McGregor S et al. Randomised trial of personalised computer based information for cancer patients. BMJ 1999; 319(7219):1241–7.

Evidence Table 6

Description of consumer characteristics in RCTs addressing the impact of CHI applications on intermediate outcomes (KQ1b)

Author, Year | Control Intervention | Age | Race, n(%) | Income | Education, n (%) | SES | Gender, n (%) | Marital Status | Other characteristics
Breast cancer
Gustafson, 2001^1^ | Allocated standard intervention | Mean, 44.4 SD, 7.1 | White non-Hispanic (72) | USD 40,000, (50.8) | 12–16yr,( 40.2) | NR | | Living with partner, (72.6) | Insurance: Private Insurance, (84.7)
Gustafson, 2001^1^ | Received CHESS intervention, a home based computer system | Mean, 44.3 SD, 6.6 | White non-Hispanic (76) | USD 40,000, (58.1) | 12–16 yr, (45.8) | NR | | Living with partner, (71.9) | Insurance: Private Insurance, (86)
Gustafson, 2008^2^ | Usual Care with books | NS | NS | NS | NS | NS | NS | NS | NS
Gustafson, 2008^2^ | | NS | NS | NS | NS | NS | NS | NS | NS
Breast cervical prostate and laryngeal cancer
Jones, 1999^3^ | Booklet information | NS | NS | NS | NS | NS | NS | NS | NS
Jones, 1999^3^ | | NS | NS | NS | NS | NS | NS | NS | NS

NS= Not Specified, SD= Standard Deviation, SES= Socioeconomic Status, Yr= year, USD = United States Dollar

Reference List

1 Gustafson DH, Hawkins R, Pingree S et al. Effect of computer support on younger women with breast cancer. J Gen Intern Med 2001; 16(7):435–45.

2 Gustafson DH, Hawkins R, Mctavish F et al. Internet-based interactive support for cancer patients: Are integrated systems better? 2008; 58(2):238–57.

3 Jones R, Pearson J, McGregor S et al. Randomised trial of personalised computer based information for cancer patients. BMJ 1999; 319(7219):1241–7.

Evidence table 7

Outcomes in studies addressing KQ1b, impact of CHI application on intermediate outcomes

Author, year | Outcomes | Control Intervention | n | Measure at BL | Measure at time point 2 | Measure at final time point | Mean difference (95% CI) | Significance
Gustafson,2001^1^ | Social Support | Control | 125 | | 2 month mean,78.4 | 5 month mean, 79.3 | 2 mos: 2.4 (−1.2–5.9) 5 mos: 4.9 (1.4–8.4) | 2 mos: NS 5 mos: p <0.01
Gustafson,2001^1^ | Social Support | CHESS | 121 | | 2 month mean,80.2 | 5 month mean, 84.2 | 2 mos: 2.4 (−1.2–5.9) 5 mos: 4.9 (1.4–8.4) | 2 mos: NS 5 mos: p <0.01
Gustafson,2001^1^ | Information competence | Control | 125 | | 2 month mean, 65.6 | 5 month mean, 65.8 | 2 mos: 4.8 (1.5–8.1) 5 mos: 3,5 (0.0–6.9) | 2 mos: p <0.01 5 mos: p 0.05
Gustafson,2001^1^ | Information competence | CHESS | 121 | | 2 month mean, 70.4 | 5 month mean, 69.3 | 2 mos: 4.8 (1.5–8.1) 5 mos: 3,5 (0.0–6.9) | 2 mos: p <0.01 5 mos: p 0.05
Gustafson,2001^1^ | Unmet information needs | Control | 125 | | 2 month mean, 67.2 | 5 month mean, 69.6 | 2 mos: 2.8 (−2.7-8.4 5 mos: -2.6 (−8.2–2.9) | 2 mos: NS 5 mos: NS
Gustafson,2001^1^ | Unmet information needs | CHESS | 121 | | 2 month mean, 70.0 | 5 month mean, 67.0 | 2 mos: 2.8 (−2.7-8.4 5 mos: -2.6 (−8.2–2.9) | 2 mos: NS 5 mos: NS
Gustafson,2001^1^ | Participation, behavioral involvement | Control | 125 | | 2 month mean, 73.1 | 5 month mean, 72.8 | 2 mos: 2.5 (−1.1–6.1) 5 mos: 1.7 (−2.3–5.6) | 2 mos: NS 5 mos: NS
Gustafson,2001^1^ | Participation, behavioral involvement | CHESS | 121 | | 2 month mean, 75.6 | 5 month mean, 74.5 | 2 mos: 2.5 (−1.1–6.1) 5 mos: 1.7 (−2.3–5.6) | 2 mos: NS 5 mos: NS
Gustafson,2001^1^ | Participation, level of comfort | Control | 125 | | 2 month mean, 74.3 | 5 month mean, 76.5 | 2 mos: 6.4 (2.1–10.7) 5 mos: 2.6 (−1.4–6.7) | 2 mos: p <0.01 5 mos: NS
Gustafson,2001^1^ | Participation, level of comfort | CHESS | 121 | | 2 month mean, 80.7 SD, | 5 month mean, 79.1 | 2 mos: 6.4 (2.1–10.7) 5 mos: 2.6 (−1.4–6.7) | 2 mos: p <0.01 5 mos: NS
Gustafson,2001^1^ | Confidence in doctors | Control | 125 | | 2 month mean, 77.3 | 5 month mean, 79.0 | 2 mos: 5.7 (1.0–11.3) 5 mos: 3.8 (−2.2–9.8) | 2 mos: p <0.05 5 mos: NS
Gustafson,2001^1^ | Confidence in doctors | CHESS | 121 | | 2 month mean, 83.0 | 5 month mean, 82.8 | 2 mos: 5.7 (1.0–11.3) 5 mos: 3.8 (−2.2–9.8) | 2 mos: p <0.05 5 mos: NS

| | | 2 month | | Effect size (p value) | 4 month | | Effect size (p value) | 9 month | | Effect size (p value)
Gustafson,2008^2^ | Social support | Control | 83 | CHESS minus control: mean, 0.16 SD, 0.49 | 0.32 (0.039) | 78 | CHESS minus control: mean, 0.25 SD, 0.53 | 0.46 (0.004)** | 75 | CHESS minus control: mean, 0.21 SD, 0.55 | 0.38 (0.021)*
Gustafson,2008^2^ | Social support | Internet | 79 | Internet minus control: mean, −0.08 SD, 0.56 | −0.14 (.39) | 80 | Internet minus control: mean, −0.03 SD, 0.60 | 0.05 (0.77) | 75 | Internet minus control: mean, 0.06 SD, 0.58 | 0.10 (0.57)
Gustafson,2008^2^ | Social support | CHESS | 90 | CHESS minus Internet: mean, 0.16 SD, 0.49 | 0.47 (0.003)** | 85 | CHESS minus Internet: mean, 0.20 SD, 0.56 | 0.35 (0.027) | 80 | CHESS minus Internet: mean,0.13 SD, 0.54 | 0.24 (0.14)
Gustafson,2008^2^ | Health & information competence | Control | 83 | CHESS minus control: mean, 0.12 SD, 0.47 | 0.25 (0.126) | 78 | CHESS minus control: mean, 0.07 SD, 0.40 | 0.17 (0.32) | 75 | CHESS minus control: mean, 0.18 SD, 0.48 | 0.38 (0.028)
Gustafson,2008^2^ | Health & information competence | Internet | 79 | Internet minus control: mean, −0.03 SD, 0.48 | −0.06 (0.69) | 80 | Internet minus control: mean, −0.05 SD, 0.45 | −0.10 (.53) | 75 | Internet minus control: mean, 0.06 SD, 0.49 | 0.12 (0.48)
Gustafson,2008^2^ | Health & information competence | CHESS | 90 | CHESS minus Internet: mean, 0.17 SD, 0.39 | 0.44 (0.007)** | 85 | CHESS minus Internet: mean, 0.19 SD, 0.40 | 0.23 (0.15) | 80 | CHESS minus Internet: mean, 0.12 SD, 0.37 | 0.24 (0.16)

Author, year | Outcomes | Control intervention | n | No. (%) 95% CI on % | P value of difference Personal vs. general information on computer | P value of difference Computer vs. booklet
Jones, 1999^3^ | Satisfaction Score >2 No. (%) a few days after information given | Booklet | 150 | 58 (40) 32 to 48 | 0.04 (personal better) | 0.77
Jones, 1999^3^ | Satisfaction Score >2 No. (%) a few days after information given | Computer- Personal Information via computer | 156 | 68 (46) 38 to 54
Jones, 1999^3^ | Satisfaction Score >2 No. (%) a few days after information given | Computer - General information about cancer | 128 | 41 (34) 26 to 42
Jones, 1999^3^ | Prefer computer to 10 minute consultation with professional (at 3 months of follow up) | Booklet | 150 | 12/122(10)
Jones, 1999^3^ | Prefer computer to 10 minute consultation with professional (at 3 months of follow up) | Computer- Personal Information via computer | 156 | 38/131(29)
Jones, 1999^3^ | Prefer computer to 10 minute consultation with professional (at 3 months of follow up) | Computer - General information about cancer | 128 | 22/110 (20) | 0.12 | <0.001 (computer more likely)

* “p<0.05. CHESS vs. control and Internet vs. control comparisons share alpha, thus p<0.025 for significance”

** “p<0.01. CHESS vs. control and Internet vs. control comparisons share alpha, thus p<0.025 for significance”

NS = not significant, CHESS = Comprehensive Health Enhancement Support System, SD = standard deviation, mos = months, BL = baseline, CI = confidence interval

Reference List

1 Gustafson DH, Hawkins R, Pingree S et al. Effect of computer support on younger women with breast cancer. J Gen Intern Med 2001; 16(7):435–45.

2 Gustafson DH, Hawkins R, Mctavish F et al. Internet-based interactive support for cancer patients: Are integrated systems better? 2008; 58(2):238–57.

3 Jones R, Pearson J, McGregor S et al. Randomised trial of personalised computer based information for cancer patients. BMJ 1999; 319(7219):1241–7.

Evidence Table 8

Description of RCTs addressing KQ1b (impact of CHI applications on intermediate outcomes)

Author, year | Consumer under study | CHI Application type | Location | Year data collected/duration of intervention | Inclusion criteria | Exclusion criteria | Control | Intervention | Jadad score
Diet/exercise/physical activity NOT obesity
Adachi, 2007^1^ | Individuals interested in their own health care | Tailored advice based on answers to a Computerized questionnaire | Home/residence | 2002/January to September | 20–65 yr, BMI greater ≥24, BMI greater ≥ 23 with mild Hypertension, Hyperlipidemia, or DM | BMI ≥30, history of major medical or psychiatric problems or orthopedic problems that prohibited exercise, received a diet and/or exercise program within 6 months, currently/previously/planned to be pregnant within 6 months | Untailored self-help booklet with 7-month self monitoring of weight and walking; Self-help booklet only | Computerized behavioral weight control program with 6-month weight and targeted behavior’s self-monitoring; computerized behavioral weight control program only | 0
Anderson, 2001^2^ | Consumers interested in their own health | Interactive computer based program | Kiosk based computers located in supermarkets | NS | NS | NS | No intervention- control condition | Computerized nutrition intervention
Brug, 1998^3^ | General public interested in their own health | Computer-generated feedback letters | Home based | NS | NS | NS | General Information | Tailored Feedback; Tailored + Iterative Feedback
Brug, 1999^4^ | Individuals interested in their own health | Computer-tailored nutrition education | Computer based; otherwise non-specified | NS | NS | NS | First intervention (comparison group) provided subjects with personal letters with tailored dietary feedback about fat, fruit and vegetables only | The second intervention (experimental group), tailored letters with dietary feedback was supplemented by feedback about personal outcome expectancies, perceived social influences and self-efficacy expectations
Campbell 1994^5^ | Adult patients from four North Carolina family practices | individually computer-tailored nutrition messages | Home based | Between September and November 1991 | Office staff recruited participants as they checked in for any type of medical appointment. | patients who were too ill or mentally unable to complete the baseline survey | Messages were mailed to participants | An intervention group, which received tailored nutrition messages; a comparison intervention group, which received nontailored nutrition messages; The tailored intervention consisted of a one-time, mailed nutrition information packet tailored to the participant's stage of change, dietary intake, and psychosocial information.
Campbell, 1999^6^ | Low income women enrolled in the Food Stamp program | Interactive computer based program | Facility based (food stamp office) | January through April, 1995 | 18 years of age or older, spoke English and either had children under 18 living at home or were pregnant | NS | No Intervention | Computer-based intervention consisted of a tailored soap opera and interactive ‘info-mercials’ that provided individualized feedback about dietary fat intake, knowledge and strategies for lowering fat based on stage of change
Campbell, 2004^7^ | Participants in the Special Supplemental Nutrition Program for Women, Infants and Children (WIC) | CDROM program | Clinic-based | NS | Being at least 18 years of age, receiving WIC benefits for self or child(ren), and speaking and understanding English. For those women who were pregnant or breast-feeding, it was required that they have at least one prior nutrition session with a WIC nutritionist before being referred to the computer program | Women deemed as high risk by the nutritionist (eg, owing to pregnancy complications) were excluded from the study because of the probable need for more intensive counseling and follow-up. | Control group completed the surveys but did not receive the intervention until after follow-up | Interactive tailored nutrition education
Haerens, 2005^8^ | Middle school adolescents) | Computer-tailored feedback | School based | Measures were assessed at the beginning (September 2003) and repeated at the end of the school year (June 2004). | NS | NS | No intervention | Intervention with parental support and intervention alone
Haerens, 2007^9^ | Individuals interested in their own health care (students in randomly selected 7th grade class) | Interactive computer-tailored intervention | Remote location: school | Year, 2005 (November)/50 minute intervention with 3 month follow up | 7th grade students, parental consent | | No intervention | 50-min class (in 7th grade) using the computer tailored dietary fat intake intervention | 0
Haerens, 2009^10^ | Adolescent population | Web-based computer tailored intervention | Home Based | February–March 2007 | NS | NS | Generic feedback letter | Tailored Feedback letter
Hurling, 2006^11^ | Individuals interested in their own health | Internet-based exercise motivation and action support system (Test system) | Computer based; otherwise non-specified | NS | NS | taking of prescription medication, known heart conditions or related symptoms and receipt of advice from a health professional not to engage in physical activity or exercise | Non-interactive Internet-based physical activity system) | Interactive Internet-based physical activity system)
Hurling, 2007^12^ | Individuals interested in their own health care | Internet and mobile phone for self reported physical activity | Home/residence | Duration, 3 month, September to December, 2005. | 30–55 yr, Body mass index 19–30, Not vigorously active, Not taking regular prescription medication, Internet and e-mail access, Mobile phone user | Employee of Unilever, 1 or more items on the PAR-Q, 1 or more items on the Rose Angina Questionnaire | No intervention | Internet and mobile phone based intervention | 2
King, 2006^13^ | people with type 2 diabetes | Interactive CDROM | Facility based | NS | At least 25 years old; diagnosed with type 2 diabetes for 6 months or more; able to read and write in English; and able to perform moderate level PA | NS | generic health risk appraisal CD-ROM | Interactive CD-ROM
Kristal, 2000^14^ | Enrollees of a large health maintenance organization | Computer-generated personalized letter and computer generated behavioral feedback | Home-based | NS | GHC enrollment, age (18–69) and an ability to complete the baseline survey in English. | Living outside of area or no longer enrolled in GHC | Usual Care Group (no intervention) | Tailored, Self-Help Dietary Intervention
Lewis, 2008^15^ | Sedentary adults interested in their own health | Web-based computer-tailored Feedback | Computer/Home based | January 2003 through May 2006 | NS | NS | Standard Internet | Motivationally-Tailored Internet
Low, 2006^16^ | Individuals interested in their own health care | Interactive consumer website (Student Bodies, | NS | 2001 | (F) first or second year college, northeast private, liberal arts college | Women with previous diagnosis of eating disorders or who were currently purging, | Control | Student Bodies with moderated discussion, Student Bodies with un-moderated discussion, Student Bodies with no discussion | 2
Mangunkusumo, 2007^17^ | Individuals interested in their own health care: student--with parental consent | Internet site | Remote location (e.g. library internet cafe); at a secondary school | NS | Secondary school students of the same grade | | Preprinted generic advice on fruit consumption and a mailed referral where applicable after baseline assessment | Tailored feedback on fruit consumption and an online referral where applicable after baseline assessment | 1
Marcus, 2007^18^ | Individuals interested in their own health care | Interactive consumer website | Home/residence | 15 Jan 2003 through 6 June 2006 | ≥18 yr, sedentary (<90 minutes of physical activity each week) | History of coronary or valvular heart disease, Hypertension, Diabetes mellitus, chronic obstructive pulmonary disease, stroke, osteoarthritis, orthopedic problems that would limit treadmill testing, or any other serious medical condition that would make physical activity unsafe or unwise, consuming 3 or more alcoholic drinks per day on 5 or more days of the week, Current or planned pregnancy, planning to move from the area within the next year, current suicidal ideation or psychosis, current clinical depression and/or hospitalization because of a psychiatric disorder in the past 6 months, current clinical depression and/or hospitalization because of a psychiatric disorder in the past 6 months, taking medication that may impair physical activity tolerance or performance , and/or previous participation in exercise trials of authors | | Tailored print, Tailored internet, Standard internet | 3
Napolitano, 2003^19^ | Individuals interested in their own health care | Interactive consumer website | Home/residence, Remote location: work place | 12 weeks | 18–65 years old, 120 minutes or less of moderate intensity physical activity per week, 60 minutes or less of vigorous intensity physical activity per week | Coronary artery disease, Stroke, Alcoholism or substance abuse, Hospitalization for a psychiatric disorder in the last 3 years, Currently suicidal or psychotic, Orthopedic problems that could limit exercise, and current or planned pregnancy | Wait list control group | Internet web site plus weekly email tip sheets | 0
Oenema, 2001^20^ | Individuals interested in their own health care | Interactive consumer website, | Classroom or office of adult education institutes (sites of recruitment) | NS | | Insufficient understanding of Dutch | Non-tailored nutrition information letter | Received we-based tailored nutrition education program | 0
Richardson, 2007 21 | Sedentary adults with type II Diabetes | Enhanced pedometers with embedded USB ports, uploaded detailed, time-stamped step-count data to a website called Stepping Up to Health; and received automated step-count feedback, automatically calculated goals, and tailored motivational messages | Home/residence | NS | At least 18 years of age and had type 2 diabetes. Eligible participants also reported regular e-mail use, and had access to an Internet-connected computer with a Windows 2000 or XP operating system and an available USB. Participants also had to be able to communicate in English, provide written consent, and obtain medical clearance to start a walking program from a primary care physician, endocrinologist, or cardiologist. | If they had used a pedometer in the past 30 days or were pregnant. | Participants randomized to receive LG were instructed to focus on total accumulated steps. | Participants randomized to receive SG were instructed to focus on bout steps. They were encouraged to set their pedometer to display bout steps (labeled aerobic steps on the Omron pedometers), and they were assigned weekly automatically calculated bout steps goals based only on bout-step data uploaded from the previous week.
Smeets, 2007^22^ | Individuals interested in their own health care | Tailored newsletter computer generated based on information about the Individuals | Home/residence | 15 months | 18–65 yr, | | Control group receiving one general information letter | Intervention group, receiving one tailored letter | -1
Spittaels, 2007^23^ | Healthy adults interested in their own health | Web based | Home based | NS | 20 and 55 years of age, had no history of cardiovascular diseases, and had access to the Internet | NS | No intervention | website-delivered physical activity intervention –with or without computer tailored feedback
Spittaels, 2007^24^ | Individuals interested in their own health care | Interactive consumer website | Work | NS | 25–55 yr, internet access at home or work | History of cardiovascular disease | Online non-tailored standard physical activity advice | Online tailored physical activity advice + email, Online tailored physical activity advice only | 1
Tan, 2005^25^ | Individuals interested in their own health care | Interactive consumer website | Home/residence, Remote location: work place, | NS | 18–65 yr, Command of Dutch language, Access to computer with a CD-ROM | | No information | Tailored information, Generic information | 1
Vandelanotte, 2005^26^ | Individuals interested in their own health care | Interactive computer-tailored intervention | University computer lab | NS | 20–60 yr | Complaints related to physical activity, Complaints related to fat intake (cardiovascular disease, diabetes, anorexia, problems with stomach, liver, gallbladder or intestine) | Tailored physical activity and fat intake Interventions after 6 month FU | Tailored physical activity and fat intake intervention at baseline, Tailored physical activity intervention at baseline and tailored fat intake intervention at 3 months, Tailored fat intake at baseline, and tailored physical activity at 3 months | 1
Verheijden, 2004^27^ | Individuals interested in their own health care | Interactive consumer website | Home/residence | Duration, Baseline collected between September 2002 to December 2002 with 8 month follow up | Greater than or equal to 40 years old, Diabetes mellitus type 2, Hypertension, Dyslipidemia | No internet access | Usual care | Usual care plus web-based nutrition counseling and social support program | 0
Wylie-Rosett, 2001^28^ | Individuals (BMI > 25 kg/m2) in a freestanding health maintenance organization | Computerized tailoring | Kiosk based | NS | BMI > 25 kg/m2+ one cardiovascular risk factor | Intention to move beyond commuting distance | Work book only | Computer tailored feedback; computer tailored feedback plus staff consultation
Eating disorder
Winzelberg, 2000^29^ | Individuals interested in their own health care | Interactive consumer website | Home/residence | NS | (F), West coast public university students Desire to improve body image satisfaction | History of Bulimia or anorexia, currently engaged in purging activities, BMI below 18 | No intervention | Interactive consumer web site | 0
Nutrition intervention
Bruge, 1996^30^ | Individuals interested in their own health care | Interactive consumer website | NS | NS | Employees of Royal Shell laboratory in Amsterdam, Netherlands | | Non-tailored group; general nutrition information | Tailored group; computer generated feedback letters | 2
Silk, 2008^31^ | Individuals interested in their own health care Mothers or pregnant | Interactive consumer website | Home/residence, Remote location: community agency or extension service office | 2 weeks | 18–50 years, (F), one or more children or pregnant, poverty (yearly income less than or equal to 185% of the federal poverty index | | Pamphlet | Website Video Game | 0
Overweight and binge eating
Jones, 2008^32^ | Individuals interested in their own health care | Interactive consumer website | NS | 2005; 16 weeks | ≥85th percentile for age-adjusted BMI, binge eating or overeating behaviors at a frequency of ≥1 times per week in the previous 3 months, access to a computer and the Internet, not currently enrolled in a formal binge eating or weight loss program (eg, Weight Watchers), absence of any medical condition in which the actual condition or treatment affects weight and/or appetite, absence of anorexia nervosa and bulimia nervosa | | Wait list control group | SB2-BED | 1

NS = not specified, yr = year

Reference List

1 Adachi Y, Sato C, Yamatsu K, Ito S, Adachi K, Yamagami T. A randomized controlled trial on the long-term effects of a 1-month behavioral weight control program assisted by computer tailored advice. Behav Res Ther 2007; 45(3):459–70.

2 Anderson ES, Winett RA, Wojcik JR, Winett SG, Bowden T. A computerized social cognitive intervention for nutrition behavior: Direct and mediated effects on fat, fiber, fruits, and vegetables, self-efficacy, and outcome expectations among food shoppers. 2001; 23(2):88–100.

3 Brug J, Glanz K, Van Assema P, Kok G, Van Breukelen GJP. The Impact of Computer-Tailored Feedback and Iterative Feedback on Fat, Fruit, and Vegetable Intake. 1998; 25(4):517–31.

4 Brug J, Steenhuis I, Van Assema P, Glanz K, De Vries H. Computer-tailored nutrition education: Differences between two interventions. 1999; 14(2):249–56.

5 Campbell MK, DeVellis BM, Strecher VJ, Ammerman AS, DeVellis RF, Sandler RS. Improving dietary behavior: The effectiveness of tailored messages in primary care settings. 1994; 84(5):783–7.

6 Campbell MK, Honess-Morreale L, Farrell D, Carbone E, Brasure M. A tailored multimedia nutrition education pilot program for low-income women receiving food assistance. 1999; 14(2):257–67.

7 Campbell MK, Carbone E, Honess-Morreale L, Heisler-MacKinnon J, Demissie S, Farrell D. Randomized trial of a tailored nutrition education CD-ROM program for women receiving food assistance. 2004; 36(2):58–66.

8 Haerens L, De Bourdeaudhuij I, Maes L, Vereecken C, Brug J, Deforche B. The effects of a middle-school healthy eating intervention on adolescents' fat and fruit intake and soft drinks consumption. 2007; 10(5):443–9.

9 Haerens L, Deforche B, Maes L, Brug J, Vandelanotte C, De Bourdeaudhuij I. A computer-tailored dietary fat intake intervention for adolescents: results of a randomized controlled trial. Ann Behav Med 2007; 34(3):253–62.

10 Haerens L, Maes L, Vereecken C, De Henauw S, Moreno L, De Bourdeaudhuij I. Effectiveness of a computer tailored physical activity intervention in adolescents compared to a generic advice. Patient Educ Couns 2009.

11 Hurling R, Fairley BW, Dias MB. Internet-based exercise intervention systems: Are more interactive designs better? 2006; 21(6):757–72.

12 Hurling R, Catt M, Boni MD et al. Using internet and mobile phone technology to deliver an automated physical activity program: randomized controlled trial. J Med Internet Res 2007; 9(2):e7.

13 King DK, Estabrooks PA, Strycker LA, Toobert DJ, Bull SS, Glasgow RE. Outcomes of a multifaceted physical activity regimen as part of a diabetes self-management intervention. 2006; 31(2):128–37.

14 Kristal AR, Curry SJ, Shattuck AL, Feng Z, Li S. A randomized trial of a tailored, self-help dietary intervention: The puget sound eating patterns study. 2000; 31(4):380–9.

15 Lewis B, Williams D, Dunsiger S et al. User attitudes towards physical activity websites in a randomized controlled trial. Prev Med 2008; 47(5):508–13.

16 Low KG, Charanasomboon S, Lesser J et al. Effectiveness of a computer-based interactive eating disorders prevention program at long-term follow-up. Eat Disord 2006; 14(1):17–30.

17 Mangunkusumo R, Brug J, Duisterhout J, de Koning H, Raat H. Feasibility, acceptability, and quality of Internet-administered adolescent health promotion in a preventive-care setting. Health Educ Res 2007; 22(1):1–13.

18 Marcus BH, Lewis BA, Williams DM et al. A comparison of Internet and print-based physical activity interventions. Arch Intern Med 2007; 167(9):944–9.

19 Napolitano MA, Fotheringham M, Tate D et al. Evaluation of an internet-based physical activity intervention: a preliminary investigation. Ann Behav Med 2003; 25(2):92–9.

20 Oenema A, Brug J, Lechner L. Web-based tailored nutrition education: results of a randomized controlled trial. Health Educ Res 2001; 16(6):647–60.

21 Richardson CR, Mehari KS, McIntyre LG et al. A randomized trial comparing structured and lifestyle goals in an internet-mediated walking program for people with type 2 diabetes. Int J Behav Nutr Phys Act 2007; 4:59.

22 Smeets T, Kremers SP, Brug J, de Vries H. Effects of tailored feedback on multiple health behaviors. Ann Behav Med 2007; 33(2):117–23.

23 Spittaels H, De Bourdeaudhuij I, Vandelanotte C. Evaluation of a website-delivered computer-tailored intervention for increasing physical activity in the general population. 2007; 44(3):209–17.

24 Spittaels H, De Bourdeaudhuij I, Brug J, Vandelanotte C. Effectiveness of an online computer-tailored physical activity intervention in a real-life setting. Health Educ Res 2007; 22(3):385–96.

25 Oenema A, Tan F, Brug J. Short-term efficacy of a web-based computer-tailored nutrition intervention: main effects and mediators. Ann Behav Med 2005; 29(1):54–63.

26 Vandelanotte C, De Bourdeaudhuij I, Sallis JF, Spittaels H, Brug J. Efficacy of sequential or simultaneous interactive computer-tailored interventions for increasing physical activity and decreasing fat intake. Ann Behav Med 2005; 29(2):138–46.

27 Verheijden M, Bakx JC, Akkermans R et al. Web-based targeted nutrition counselling and social support for patients at increased cardiovascular risk in general practice: randomized controlled trial. J Med Internet Res 2004; 6(4):e44.

28 Wylie-Rosett J, Swencionis C, Ginsberg M et al. Computerized weight loss intervention optimizes staff time: The clinical and cost results of a controlled clinical trial conducted in a managed care setting. 2001; 101(10):1155–62.

29 Winzelberg AJ, Eppstein D, Eldredge KL et al. Effectiveness of an Internet-based program for reducing risk factors for eating disorders. J Consult Clin Psychol 2000; 68(2):346–50.

30 Brug J, Steenhuis I, Van Assema P, De Vries H. The impact of a computer-tailored nutrition intervention. 1996; 25(3):236–42.

31 Silk KJ, Sherry J, Winn B, Keesecker N, Horodynski MA, Sayir A. Increasing nutrition literacy: testing the effectiveness of print, web site, and game modalities. J Nutr Educ Behav 2008; 40(1):3–10.

32 Jones M, Luce KH, Osborne MI et al. Randomized, controlled trial of an internet-facilitated intervention for reducing binge eating and overweight in adolescents. Pediatrics 2008; 121(3):453–62.

Evidence Table 9

Description of consumer characteristics in RCTs addressing KQ 1b (impact of CHI applications on intermediate outcomes)

Author,year | Control Interventions | Age | Race, n(%) | Income | Education, n(%) | SES | Gender, n (%) | Marital Status, n(%) | Other
diet/exercise/physical activity NOT obesity
Adachi, 2007^1^ | Control | Mean, 46.3 SD, 8.6 | NS | NS | NS | NR | | | Height (cm): mean, 157.6 SD, 5.9 Body weight (kg): mean, 65.1 SD, 6.4 BMI (kg/m2): mean, 26.1 SD, 1.6
Adachi, 2007^1^ | Behavioral weight control program with 6-month weight and targeted behavior’s self-monitoring | Mean, 46.6 SD, 10.1 | NS | NS | NS | NR | | | Height: mean, 157.5 SD, 6.1 Body weight (kg): mean, 65.3 SD, 6.4 BMI (kg/m2): mean, 26.2 SD, 1.4
Adachi, 2007^1^ | Untailored self-help booklet with 7-month self monitoring | Mean, 46.6 SD, 9 | NS | NS | NS | NR | | | Height: mean, 155.7 SD, 5.2 Body weight (kg): mean, 63.4 SD, 5.5 BMI (kg/m2): mean, 26.1 SD, 1.5
Adachi, 2007^1^ | Behavioral weight control program | Mean, 45.3 SD, 10.4 | NS | NS | NS | NR | | | Height: mean, 157.0 SD, 5.5 Body weight (kg): mean, 64.8 SD, 6.5 BMI (kg/m2): mean 26. SD, 1.5
Anderson, 2001^2^ | Control | NS | NS | NS | NS | NS | NS
Anderson, 2001^2^ | Intervention | NS | NS | NS | NS | NS | NS
Anderson, 2001^2^ | Sample statistics | NS | White (92) | Median annual $35,000; $20,000 or less (12) | Mean years of education 14.78±2.11; 12 years or fewer (20) | NS | F (96) | | .70 children (SD 1.00, p<.001)
Brug, 1998^3^ | Control-General Information | NS | NS | NS | NS | NS | NS | | NS
Brug, 1998^3^ | Tailored Feedback; Tailored + Iterative Feedback | NS | NS | NS | NS | NS | NS | | NS
Brug, 1998^3^ | Baseline Statistics | 44 (SD 14) years. | NS | NS | College degree (42) | NS | F (82) | | Mean body mass index was 23.7 (SD 5.9) for women and 24.6 (SD 3.7) for men.; mean fat score at baseline was 27.2 (SD 5.2); mean number of daily servings of vegetables and fruit were 1.0 (SD 0.4) and 2.2 (SD 1.7), respectively. Mean attitude scores at baseline (on a -3 to 3 scale) were 2.0 (SD 1.4) toward fat reduction and 2.5 (SD 0.8) and 2.3'(SD 0.9) toward increasing vegetables and fruit. Self-efficacy (range -3 to 3) expectations were 0.6 (SD 1.8), 1.3 (SD 1.7), and 1.2 (SD 1.9) toward reducing fat and increasing vegetables and fruit, respectively.
Brug, 1999^4^ | Comparison 163 | M 41.3 | NS | NS | NS | NS | NS | | BMI 23.9
Brug, 1999^4^ | Experimental 152 | M 38.6 | NS | NS | NS | NS | NS | | BMI 24.2
Campbell, 1994^5^ | No messages (124) | NS | NS | NS | NS | NS | NS | | NS
Campbell, 1994^5^ | Tailored messages (134) | NS | NS | NS | NS | NS | NS | | NS
Campbell, 1994^5^ | Non-tailored messages (136) | NS | NS | NS | NS | NS | NS | | NS
Campbell, 1994^5^ | Baseline characteristics | Average age of 40.8 years | Minority enrollment (19.0) | Median annual household level was $30 000 to $39 000, | (mean 13.6 years), | NS | F (75.3) | | NS
Campbell, 1999^6^ | Control 212 | 28.9 (0.59) | Caucasian 10.8 African-American 82.1 Hispanic 1.9 American Indian 1.9 other ethnicity 3.3 | NS | Less than high school (33.0) high school graduate or GED ( 36.3) beyond high school (30.7) | NS | NS | | Mean child number (SE) 2.1 (0.09) High autonomy (71.2) Feel need to lose weight (62.3)
Campbell, 1999^6^ | Intervention 165 | 30.2 (0.67) | Caucasian 7.3 African-American 87.3 Hispanic 1.2 American Indian 0.6 other ethnicity 3.6 | NS | Less than high school (33.9) High school graduate or GED (37.0) beyond high school (29.1) | NS | NS | | Mean child number (SE) 2.2 (0.10) High autonomy (77.0) Feel need to lose weight (59.4)
Campbell, 2004^7^ | Control-No intervention (166) | 27.5 (8.6) | African American 26.7; White non-Hispanic 60.6; Other 12.7 | NS | High school 17.1; High school or GED 67.1; Beyond high school (any trade/beauty school/college) 15.8 | NS | F(97) | | Pregnant (19), Breast-feeding (5); Number of children, mean (SD) 2.0 (1.1)
Campbell, 2004^7^ | Computer tailored interactive nutrition education (141) | 27.3 (7.9) | African American 39.7; White non-Hispanic 48.9; Other 12.7 | NS | High school 21.3; High school or GED 66.7; Beyond high school (any trade/beauty school/college) 12.0 | NS | F(98) | | Pregnant (23); Breast-feeding (4) Number of children, mean (SD) 1.9 (1.0)
Haerens, 2005^8^ | Control condition (n 5 schools, 759 pupils) | 12.85 (0.71) | NS | NS | NS | Lower SES (52.4) | Girls (58.8) | | NS
Haerens, 2005^8^ | Intervention with parental support(n schools, 1226 pupils) | 13.04 (0.79) | NS | NS | NS | Lower SES (68.0) | Girls (40.1) | | NS
Haerens, 2005^8^ | Intervention alone (n 5 schools, 1006 pupils) | 13.24 (0.87) | NS | NS | NS | Lower SES (78.9) | Girls (15.6) | | NS
Haerens, 2007^9^ | No intervention | Mean, 13.2 SD, 0.5 | NS | NS | General, 84 (55.6) Technical-vocational, 67 (44.4) | NR | F,111 (73.5) M,40 (26.5) | | Stage of change: Pre-contemplation, 36 (24.8) Contemplation, 8 (5.5) Preparation, 12 (8.3) Action, 34 (23.4) Maintenance, 55 (37.9) Dietary fat intake: mean, 113.9 SD, 46.3
Haerens, 2007^9^ | Intervention | Mean, 13.3 SD, 0.5 | NS | NS | General, 90 (58.8) Technical-vocational, 63 (41.2) | NR | F,103 (67.3) M, 50 (32.7) | | Stage of change: Pre-contemplation, 42 (28.2) Contemplation,4 (2.7) Preparation ,11 (7.4) Action, 44 (29.5) Maintenance, 48 (32.2) Dietary fat intake: mean, 116.3 SD, 50.1
Haerens, 2009^10^ | Control- Generic feedback information | NS | NS | NS | NS | NS | NS | | NS
Haerens, 2009^10^ | Computer tailored feed back | NS | NS | NS | NS | NS | NS | | NS
Haerens, 2009^10^ | Baseline Characteristics | 14.6 _ (1.2) | NS | NS | NS | NS | (526 boys, 645 girls | | NS
Hurling, 2006^11^ | Control 22 | M 34.9 | NS | NS | NS | NS | F 78 | | NS
Hurling, 2006^11^ | Intervention 25 | M 34.0 | NS | NS | NS | NS | F72 | | NS
Hurling, 2007^12^ | No intervention | Mean, 40.1 SD, 7.7 | White non-Hispanic, (97) | NS | NS | NR | F, (70) | | Household broadband access: yes, (22) Weight in kg: mean, 73.9 SD, 10.2 BMI: mean, 26.5 SD, 4.1 Initial IPAQ self0report level of physical activity (MET min): mean, 3868SD, 2257
| Internet and mobile phone intervention | Mean, 40.5 SD, 7.1 | White non-Hispanic, (100) | NS | NS | NR | F (64) | | Household broadband access: Yes, (29) Weight in kg: mean, 75.1 SD, 11.7 BMI: mean, 166.3 SD, 6.6 Initial IPAQ self0report level of physical activity (MET min): mean, 4350 SD, 3200
King, 2006^13^ | Generic health risk appraisal CD-ROM | 61.0 (11.0) | Hispanic (8.2) White (79.1) | Income Less than $10,000 5.3 $10,000 to $29,999 20.0 $30,000 to $49,999 35.3 $50,000 to $69,999 18.7 $70,000 to $89,999 12.0 $90,000 or more 11.9 | Completed high school (27.4) Technical school (37.6) Completed college (22.9) Graduate degree (12.1) | NS | F(51.3) | | Married (63.7); Taking insulin (19.1); Body mass index (kg/m2) (M, SD)) 31.9 (7.2); Comorbiditiesd (M, SD) 3.1 (2.1); Smokers 11.9
King, 2006^13^ | Interactive CD-ROM | 61.9 (11.7) | Hispanic (17.4) White (74.3) | Income Less than $10,000 4.8 $10,000 to $29,999 24.8 $30,000 to $49,999 27.0 $50,000 to $69,999 20.0 $70,000 to $89,999 9.7 $90,000 or more 8.2 | Completed high school (27.4) Technical school (37.6) Completed college (22.9) Graduate degree (12.1) | NS | F(50.0) | | Married (67.8); Taking insulin (24.7); Body mass index (kg/m2) (M, SD) 31.4 (7.0) ; Comorbiditiesd (M, SD) 2.9 (1.9) ; Smokers (8.2)
Kristal, 2000^14^ | Usual Care (730) | NS | NS | NS | NS | NS | NS | | NS
Kristal, 2000^14^ | Intervention (729) | NS | NS | NS | NS | NS | NS | | NS
Kristal, 2000^14^ | Base line characteristics | 44.9 ± 14.9 | White 85.9; Black 4.5; Asian 5.8; Hispanic 3.0; Other 0.8 | (%, $1,000),<25 (12.2); 25–34 16.9; 35–49 25.4; 50–69 23.7; 701 21.7 | NS | NS | M (50.9) | | Body mass index (x 6 SD) 26.5 6 5.0
Lewis, 2008^15^ | Standard Internet | NS | NS | NS | NS | NS | NS | | NS
Lewis, 2008^15^ | Motivationally-Tailored Internet | NS | NS | NS | NS | NS | NS | | NS
Lewis, 2008^15^ | Baseline Statistics | NS | Caucasian (76.3) | NS | NS | NS | Women (82.7) | | NS
Low, 2006^16^ | Control | NS | Students of color (8.4) | NS | NS | NR | | | NS
Low, 2006^16^ | Student bodies with a moderated discussion | NS | NS | NS | NS | NR | F (100) | | NS
Low, 2006^16^ | Student bodies with a un-moderated discussion | NS | NS | NS | NS | NR | F (100) | | NS
Mangunkusumo, 2007^17^ | Internet | Mean, 15 range, 13-17 | Dutch, (76.5) Turkish (5.0) Moroccan (3.3) Surinamese (2.4) Antillean/Arubans (0.4) Other (12.3) | NS | NS | NR | M, (43.9) | | Lower secondary/vocational, (59.1) Int. secondary, (18.6) Upper secondary, (22.3)
Mangunkusumo, 2007^17^ | Control | NS | NS | NS | NS | NR | NS | | NS
Marcus, 2007^18^ | Control | 46.3 (9.4) | NS | NS | NS | NR | | | NS
Marcus, 2007^18^ | Tailored print | Mean, 445 SD, 9.6 | White non-Hispanic, (77.9) | USD >50,000, (57.0) | College graduate (or doing post graduate work), (72.1) | NR | F, (83.7) | Married, (69.8) | BMI: mean, 29.1 SD, 6.2 Employment: employed, (80.2)
Marcus, 2007^18^ | Tailored internet | Mean, 44.5 SD, 9 | White non-Hispanic, (82.7) | USD >50,000, (58.0) | College graduate (or doing post graduate work), (64.2) | NR | F, (81.5) | Married, (63.0) | BMI: mean, 29.7 SD, 6.5 Employment: employed, (90.0)
Marcus, 2007^18^ | Control | 46.3 (9.4 | White non-Hispanic, (84.1) | USD >50,000, (53.7) | College graduate (or doing post graduate work), (64.6) | NR | F, (82.9) | Married, (55.6) | BMI: mean, 29.5 SD, 5.5 Employment status: employed, (89.0)
Napolitano, 2003^19^ | Wait list control group | NS | NS | NS | NS | NR | | | NS
Napolitano, 2003^19^ | Internet | NS | NS | NS | NS | NR | | | NS
Oenema, 2001^20^ | Non-tailored nutrition information letter | NS | NS | NS | NS | NR | | | NS
Oenema, 2001^20^ | Web based tailored nutrition education | NS | NS | NS | NS | NR | | | NS
Richardson, 2007^21^ | Lifestyle Goals (LG) Group (17) | 52 ± 12 | White (76), Black (18), Other (6) | <30,000 (18), 30,000-70,000 (18), >70,000(65) | HS diploma or GED (6), Some college (47), College degree (18), Graduate degree (29) | NS | M (29) F(71) | | Baseline Average Daily Step Count 4,157 ± 1,737; Baseline BMI 38.6 ± 8.2.; Baseline Blood Pressure Systolic 133 ± 18, Diastolic 80 ± 9; On Insulin No (88), Yes (12); Internet Usage (Home) Never (6), ≤ 4 times per month (12), Several times a week (12),Almost every day (65)
Richardson, 2007^21^ | Structured Goals (SG) Group (13) | 53 ± 9 | White (77), Black (8), Other (15) | <30,000(8), 30,000-70,000 (31), >70,000 (62) | HS diploma or GED (8), Some college (15), College degree (46), Graduate degree (31) | NS | M (38) F(62) | | Baseline Average Daily Step Count 5,171 ± 1,769; Baseline BMI 35.3 ± 8.6.; Baseline Blood Pressure Systolic 136 ± 12, Diastolic 82 ± 11; On Insulin No (69), Yes (31); Internet Usage (Home) Never (23), ≤ 4 times per month (8), Several times a week (23),Almost every day (46)
Smeets, 2007^22^ | Control group receiving one general information letter | Range, 18-65 Mean, 47 SD, 11 | NS | NS | Primary or basic vocational school(10), Secondary vocational level or high school degree (42), Higher vocational school, college degree, or university degree(48) | NR | F (57) | | NS
Smeets, 2007^22^ | Computer generated tailored newsletter | NS | NS | NS | NS | NR | NS | | NS
Spittaels, 2007^23^ | No Intervention | Age in years 40.7 (5.3) | NS | NS | Higher education 72.7 | NS | F(66.7) | | Employed 87.8; Compliance with PA recommendations 37.9; Stages of change Precontemplation 6.1 Contemplation 19.8 Preparation 36.6 Action 8.4 Maintenance 29.0; BMI in kg/m2 24.1 (3.5); PA at moderate intensity in min/day 30.9 (36.4)
Spittaels, 2007^23^ | Website with computer tailored feedback | Age in years 43.3 (5.7) | NS | NS | Higher education 61.9 | NS | F (65.3) | | Employed 86.2 ; Compliance with PA recommendations 47.4; Stages of change Precontemplation 3.5 Contemplation 8.7 Preparation 40.5 Action 11.6 Maintenance 35.8; BMI in kg/m2 25.0 (3.7); PA at moderate intensity in min/day 40.9 (40.5)
Spittaels, 2007^23^ | Website without computer tailored feedback | Age in years 39.6 (5.0) | NS | NS | Higher education 67.4 | NS | F (66.7) | | Employed 84.5 ; Compliance with PA recommendations 44.2 ; Stages of change Precontemplation 6.2 Contemplation 15.5 Preparation 34.1 Action 12.4 Maintenance 31.8 ; BMI in kg/m2 24.6 (3.6) ; PA at moderate intensity in min/day 39.5 (42.3)
Spittaels, 2007^24^ | Standard advice | Range, 25-55 mean, 40.9 SD, 8 | NS | NS | College or university degree(59.6) | NR | F (27) | | BMI: mean, 24.4 SD, 3.1 Work status: Factory workers (22) Office workers (51) Managers (27) Stages of Change: Pre-contemplation (10.7) Contemplation (17.9) Preparation (10.7) Action (10.0) Maintenance (49.3)
Spittaels, 2007^24^ | Tailored advice + email | Range, 5-55 mean, 39.7 SD, 8.9 | NS | NS | College or university degree(63.4 ) | NR | F (38.8) | | BMI: mean, 24.3 SD, 3 Work status: Factory workers (22.4) Office workers (60.3) Managers (17.2) Stages of Change: Pre-contemplation (6.9) Contemplation (13.8) Preparation (11.2) Action (12.9) Maintenance (55.2)
Spittaels, 2007^24^ | Tailored advice | Range, 25-55 mean, 39.3 SD, 8.7 | NS | NS | College or university degree(68.9) | NR | F (32) | | BMI: mean, 24.4 SD, 3.5 Work status: Factory workers (21.3) Office workers (51.6) Managers (27.0) Stages of Change: Pre-contemplation (7.6) Contemplation (13.4) Preparation (10.1) Action (16.0) Maintenance (52.9)
Tan, 2005^25^ | No information | NS | NS | NS | NS | NR | | | NS
Tan, 2005^25^ | Tailored Information | NS | NS | NS | NS | NR | | | NS
Tate, 2006^26^ | No counseling | Mean, 49.9 SD, 8.3 | Minority 6(9) | NS | College graduate(49) | NR | F: 55, (82) | 49 (73) | Weight: mean, 88.3 (13.9) body mass index: 32.3 (3.7) internet experiences, y: 4.7 (2.9) Waist circumference, cm: 106.4 (11.3) Weekly internet use, h: 4.5 (4.9)
Tate, 2006^26^ | Human email counseling | Mean, 47.9 SD, 11.4 | Minority 8(13) | NS | College graduate(56) | NR | F: 54,( 84) | 53(83) | Weight: mean, 89.0 (13.0) body mass index: 32.8 (3.4) internet experiences, y: 4.1 (2.3) Waist circumference, cm: 107.4 (10.8) Weekly internet use, h: 4.7 (5.3)
Tate, 2006^26^ | Automated feedback | Mean, 47.9 SD, 9.8 | Minority 6(10) | NS | College graduate (59) | NR | F: 53,( 87) | 46(75) | Weight: mean, 89.0 (13.2) body mass index: 32.7 (3.5) internet experiences, y: 4.4 (2.2) Waist circumference, cm: 107.6 (11.2) Weekly internet use, h: 5.0 (4.2)
Vandelanotte, 2005^27^ | Control | NS | NS | NS | NS | NR | NS | | NS
Vandelanotte, 2005^27^ | Sequential Interactive computer tailored intervention | NS | NS | NS | NS | NR | NS | | NS
| Simultaneous interactive computer tailored intervention | NS | NS | NS | NS | NR | NS | | NS
Verheijden, 2004^28^ | Usual care | Mean, 64 SD, 10 | NS | NS | ≤ High school13 (18) , Intermediate22 (30), ≥ B.Sc. level38 (52) | NR | M: 43 (59) F: 30 (41) | | Lifestyle: Never smoke:28 (39) Ex-smoker: 38 (52) Current smoker: 7 (9) Alcohol >3 glasses/wk: 39 (54) mean, Exercise >3 times/wk: 45 (61) Medication use: HTN: 49 (67) Dyslipidemia:23 (31) DM type 2: 13 (18) Stage of Change: Pre-contemplation: 12 (16) Contemplation: 4 (5) Preparation: 5 (7) Action: 3 (4) mean Maintenance: 50 (68)
| Web-Based Targeted Nutrition Counseling and Social Support | Mean, 62 SD, 11 | NS | NS | ≤ High school 15 (21), Intermediate 31 (42), ≥ B.Sc. level27 (37) | NR | M: 38 (52) F: 35 (48) | | Lifestyle: Never smoker: 26 (35) Ex-smoker: 37 (51) Current smoker: 10 (14) Alcohol>3 glasses/wk: 41 (56) mean, Exercise>3 wks/wk: 46 (63) Medication use: HTN: 49 (67) Dyslipidemia: 26 (35) DM type 2: 9(13) Stage of change: Pre-contemplation: 11 (15) Contemplation: 2 (3) Preparation: 7 (1) Action: 9 (13) mean, Maintenance: 50 (68)
Wylie-Rosett, 2001^29^ | Work book only | 52.5± 11.50 | White 100(86.2) | NS | Education>1 yr in college 99 (85.3) | NS | F 88 (75.7) | | NS
Wylie-Rosett, 2001^29^ | Computer tailored feedback | 52.7± 11.27 | White 195 (82.6) | NS | Education>1 yr in college 193 (81.8) | NS | F 199 (84.3) | | NS
Wylie-Rosett, 2001^29^ | computer tailored feedback plus staff consultation | 51.6± 12.14 | White 193 (81.8) | NS | Education>1 yr in college 192 (85.6) | NS | F 197 (83.5) | | NS
Eating disorder
Bruge, 1996^30^ | Non-tailored group | Mean, 39 SD, 8 | NS | NS | University training (34) Technical degree (59) Less than high school (7) | NR | M (83) | | Fat consumption/day: 28.0(5.3) Vegetable servings/day: 1.00 (0.31) Fruit servings/day: 1.61(1.14)
Bruge, 1996^30^ | Intervention group | NS | NS | NS | NS | NR | NS | | NS
Silk, 2008^31^ | Video game | Mean, 33, SD, 8.28 | European American (68) African American (25) Latino (5) Asian (1) Other (1) | Yearly income less or equal to (185) of federal index: (100) | Less than college (87) High school or GED equivalent (44) | NR | F (100) | | NS
Silk, 2008^31^ | Web site | NS | NS | NS | NS | NR | NS | | NS
Silk, 2008^31^ | Define | NS | NS | NS | NS | NR | NS | | NS
Winzelberg, 2000^32^ | No intervention | Mean, 20 range, 18–33 SD, 2.8 | White non-Hispanic, (53) Black non-Hispanic, (3) Latino/Hispanic, (35) API, (5) Other, (3) | NS | NS | NR | F (100) | | NS
Winzelberg, 2000^32^ | Intervention | NS | NS | NS | NS | NR | NS | | NS
Overweight and binge eating
Jones, 2008^33^ | Wait list control group | Mean, 15.2 SD, 1.1 | White non-Hispanic, 32 Black non-Hispanic, 6 Latino/Hispanic, 10 API, Other, 5 | NS | Grade in school, n: 9th, 20 10th, 19 11th, 13 12th, 1 | NR | F, 35 M, 18 | | Born in United States (92) BMI: mean, 30.64 SD, 5.97
Jones, 2008^33^ | SB2-BED | Mean, 15 SD, 1 | White non-Hispanic, 35 Black non-Hispanic, 2 Latino/Hispanic, 12 Other, 3 | NS | Grade in school, n: 9th 26 10th 16 11th 10 12th 0 | NR | F, 38 M, 14 | | Born in United States :(96) BMI: mean, 30.58 SD, 4.9

NR= Not Reported, NS= Not Specified, SD= Standard Deviation, SES= Socioeconomic Status, Yr= year, CBT= Cognitive Behavioral Therapy, WL= Wait List,

BMI= Body Mass Index, QOL= Quality of Life, USD= United States Dollars, Female = F, Male = M, AIAN = American Indian/Alaska Native

Reference List

1 Adachi Y, Sato C, Yamatsu K, Ito S, Adachi K, Yamagami T. A randomized controlled trial on the long-term effects of a 1-month behavioral weight control program assisted by computer tailored advice. Behav Res Ther 2007; 45(3):459–70.

2 Anderson ES, Winett RA, Wojcik JR, Winett SG, Bowden T. A computerized social cognitive intervention for nutrition behavior: Direct and mediated effects on fat, fiber, fruits, and vegetables, self-efficacy, and outcome expectations among food shoppers. 2001; 23(2):88–100.

3 Brug J, Glanz K, Van Assema P, Kok G, Van Breukelen GJP. The Impact of Computer-Tailored Feedback and Iterative Feedback on Fat, Fruit, and Vegetable Intake. 1998; 25(4):517–31.

4 Brug J, Steenhuis I, Van Assema P, Glanz K, De Vries H. Computer-tailored nutrition education: Differences between two interventions. 1999; 14(2):249–56.

5 Dickerson S, Reinhart AM, Feeley TH et al. Patient Internet use for health information at three urban primary care clinics. J Am Med Inform Assoc 2004; 11(6):499–504.

6 Campbell MK, Honess-Morreale L, Farrell D, Carbone E, Brasure M. A tailored multimedia nutrition education pilot program for low-income women receiving food assistance. 1999; 14(2):257–67.

7 Campbell MK, Carbone E, Honess-Morreale L, Heisler-MacKinnon J, Demissie S, Farrell D. Randomized trial of a tailored nutrition education CD-ROM program for women receiving food assistance. 2004; 36(2):58–66.

8 Haerens L, De Bourdeaudhuij I, Maes L, Vereecken C, Brug J, Deforche B. The effects of a middle-school healthy eating intervention on adolescents' fat and fruit intake and soft drinks consumption. 2007; 10(5):443–9.

9 Haerens L, Deforche B, Maes L, Brug J, Vandelanotte C, De Bourdeaudhuij I. A computer-tailored dietary fat intake intervention for adolescents: results of a randomized controlled trial. Ann Behav Med 2007; 34(3):253–62.

10 Haerens L, Maes L, Vereecken C, De Henauw S, Moreno L, De Bourdeaudhuij I. Effectiveness of a computer tailored physical activity intervention in adolescents compared to a generic advice. Patient Educ Couns 2009.

11 Hurling R, Fairley BW, Dias MB. Internet-based exercise intervention systems: Are more interactive designs better? 2006; 21(6):757–72.

12 Hurling R, Catt M, Boni MD et al. Using internet and mobile phone technology to deliver an automated physical activity program: randomized controlled trial. J Med Internet Res 2007; 9(2):e7.

13 King DK, Estabrooks PA, Strycker LA, Toobert DJ, Bull SS, Glasgow RE. Outcomes of a multifaceted physical activity regimen as part of a diabetes self-management intervention. 2006; 31(2):128–37.

14 Kristal AR, Curry SJ, Shattuck AL, Feng Z, Li S. A randomized trial of a tailored, self-help dietary intervention: The puget sound eating patterns study. 2000; 31(4):380–9.

15 Lewis B, Williams D, Dunsiger S et al. User attitudes towards physical activity websites in a randomized controlled trial. Prev Med 2008; 47(5):508–13.

16 Low KG, Charanasomboon S, Lesser J et al. Effectiveness of a computer-based interactive eating disorders prevention program at long-term follow-up. Eat Disord 2006; 14(1):17–30.

17 Mangunkusumo R, Brug J, Duisterhout J, de Koning H, Raat H. Feasibility, acceptability, and quality of Internet-administered adolescent health promotion in a preventive-care setting. Health Educ Res 2007; 22(1):1–13.

18 Marcus BH, Lewis BA, Williams DM et al. A comparison of Internet and print-based physical activity interventions. Arch Intern Med 2007; 167(9):944–9.

19 Napolitano MA, Fotheringham M, Tate D et al. Evaluation of an internet-based physical activity intervention: a preliminary investigation. Ann Behav Med 2003; 25(2):92–9.

20 Oenema A, Brug J, Lechner L. Web-based tailored nutrition education: results of a randomized controlled trial. Health Educ Res 2001; 16(6):647–60.

21 Richardson CR, Mehari KS, McIntyre LG et al. A randomized trial comparing structured and lifestyle goals in an internet-mediated walking program for people with type 2 diabetes. Int J Behav Nutr Phys Act 2007; 4:59.

22 Smeets T, Kremers SP, Brug J, de Vries H. Effects of tailored feedback on multiple health behaviors. Ann Behav Med 2007; 33(2):117–23.

23 Spittaels H, De Bourdeaudhuij I, Vandelanotte C. Evaluation of a website-delivered computer-tailored intervention for increasing physical activity in the general population. 2007; 44(3):209–17.

24 Spittaels H, De Bourdeaudhuij I, Brug J, Vandelanotte C. Effectiveness of an online computer-tailored physical activity intervention in a real-life setting. Health Educ Res 2007; 22(3):385–96.

25 Oenema A, Tan F, Brug J. Short-term efficacy of a web-based computer-tailored nutrition intervention: main effects and mediators. Ann Behav Med 2005; 29(1):54–63.

26 Tate DF, Jackvony EH, Wing RR. A randomized trial comparing human e-mail counseling, computer-automated tailored counseling, and no counseling in an Internet weight loss program. Arch Intern Med 2006; 166(15):1620–5.

27 Vandelanotte C, De Bourdeaudhuij I, Sallis JF, Spittaels H, Brug J. Efficacy of sequential or simultaneous interactive computer-tailored interventions for increasing physical activity and decreasing fat intake. Ann Behav Med 2005; 29(2):138–46.

28 Verheijden M, Bakx JC, Akkermans R et al. Web-based targeted nutrition counselling and social support for patients at increased cardiovascular risk in general practice: randomized controlled trial. J Med Internet Res 2004; 6(4):e44.

29 Wylie-Rosett J, Swencionis C, Ginsberg M et al. Computerized weight loss intervention optimizes staff time: The clinical and cost results of a controlled clinical trial conducted in a managed care setting. 2001; 101(10):1155–62.

30 Brug J, Steenhuis I, Van Assema P, De Vries H. The impact of a computer-tailored nutrition intervention. 1996; 25(3):236–42.

31 Silk KJ, Sherry J, Winn B, Keesecker N, Horodynski MA, Sayir A. Increasing nutrition literacy: testing the effectiveness of print, web site, and game modalities. J Nutr Educ Behav 2008; 40(1):3–10.

32 Winzelberg AJ, Eppstein D, Eldredge KL et al. Effectiveness of an Internet-based program for reducing risk factors for eating disorders. J Consult Clin Psychol 2000; 68(2):346–50.

33 Jones M, Luce KH, Osborne MI et al. Randomized, controlled trial of an internet-facilitated intervention for reducing binge eating and overweight in adolescents. Pediatrics 2008; 121(3):453–62.

Evidence Table 10

All outcomes KQ1b, impact of CHI application on intermediate outcomes

Author, year | Outcomes | Control Intervention | n | Measure at BL | Measure at time point 2 | Measure at time point 3 | Measure at time point 4 | Measure at final time point | Ratios at time points | Significance
diet/exercise/physical activity NOT obesity
Adachi, 2007^1^ | Body Weight | Control | 50 | Mean, 65.1 SD, 6.4 | 1 month mean, −3 SD, 0.9 | 3 month mean, −1.1 SD, 1.5 | | 7 month: mean, −1.4 SD, 2.4 | | BL, time point 2, 0.01 time point 3, 0.01 final time point, 0.05
Adachi, 2007^1^ | Body Weight | Computer tailored program with 6-month weight and targeted behavior’s self-monitoring, | 36 | Mean, 65.3 SD, 6.4 | 1 month mean, −1.1 SD, 1.2 | 3 month mean, −2.3 SD, 2 | | 7 month: mean, −2.9 SD, 2.7 | | BL, time point 2, 0.01 time point 3, 0.01 final time point, 0.05
Adachi, 2007^1^ | Body Weight | Computer tailored program only, | 44 | Mean, 64.8 SD, 6.5 | 1 month mean, −0.9 SD, 1.1 | 3 month mean, −1.7 SD, 1.9 | | 7 month: mean, −2.2 SD, 3 | | BL, time point 2, 0.01 time point 3, 0.01 final time point, 0.05
Adachi, 2007^1^ | Body Weight | Untailored self-help booklet with 7-month self-monitoring of weight and walking | 53 | Mean, 63.4 SD, 5.5 | 1 month mean, −0.5 SD, 0.8 | 3 month mean, −1.3 SD, 1.5 | | 7 month: mean, −1.6 SD, 2.1 | | BL, time point 2, 0.01 time point 3, 0.01 final time point, 0.05
Adachi, 2007^1^ | BMI | Control | 50 | Mean, 26.1 SD, 1.6 | 1 month mean, −0.14 SD, 0.38 | 3 month mean, −0.44 SD, 0.6 | | 7 month mean, −0.57 SD, 0.93 | | BL, time point 2, 0.01 time point 3, 0.01 final time point, 0.05
Adachi, 2007^1^ | BMI | Computer tailored program with 6-month weight and targeted behavior’s self-monitoring | 36 | Mean, 26.2 SD, 1.4 | 1 month mean, −0.47 SD, 0.49 | 3 month mean, −0.93 SD, 0.85 | | 7 month mean, −1.22 SD, 1.16 | | BL, time point 2, 0.01 time point 3, 0.01 final time point, 0.05
Adachi, 2007^1^ | BMI | Computer tailored program only | 44 | Mean, 26.2 SD, 1.5 | 1 month mean, −0.38 SD, 0.42 | 3 month mean, −0.69 SD, 0.73 | | 7 month mean, −0.86 SD, 1.15 | | BL, time point 2, 0.01 time point 3, 0.01 final time point, 0.05
Adachi, 2007^1^ | BMI | Untailored self-help booklet with 7-month self-monitoring of weight and walking, | 53 | Mean, 26.1 SD, 1.5 | 1 month mean, −0.2 SD, 0.34 | 3 month mean, −0.53 SD, 0.64 | | 7 month mean, −0.68 SD, 0.88 | | BL, time point 2, 0.01 time point 3, 0.01 final time point, 0.05
Adachi, 2007^1^ | % weight loss | Control | 50 | | 1 month mean, −0.05 SD, 1.4 | 3 month mean, −1.6 SD, 2.3 | | 7 month mean, −2.2 SD, 3.5 | | BL, time point 2, 0.01 time point 3, 0.01 final time point, 0.05
Adachi, 2007^1^ | % weight loss | Computer tailored program with 6-month weight and targeted behavior’s self-monitoring, | 36 | | 1 month mean, −1.8 SD, 1.9 | 3 month mean, −3.6 SD, 3.3 | | 7 month mean, 4.7 SD, 4.5 | | BL, time point 2, 0.01 time point 3, 0.01 final time point, 0.05
Adachi, 2007^1^ | % weight loss | Computer tailored program only | 44 | | 1 month mean, −1.5 SD, 1.6 | 3 month mean, −2.6 SD, 2.8 | | 7 month mean, −3.3 SD, 4.3 | | BL, time point 2, 0.01 time point 3, 0.01 final time point, 0.05
Adachi, 2007^1^ | % weight loss | Untailored self-help booklet with 7-month self-monitoring of weight and walking | 53 | | 1 month mean, −0.8 SD, 1.3 | 3 month mean, −2 SD, 2.5 | | 7 month mean, −2.6 SD, 3.4 | | BL, time point 2, 0.01 time point 3, 0.01 time point 4, final time point, 0.05
Anderson, 2001^2^ | Fat (% calories) Composites Scores mean (SD) | Control | 137 | 32.74 (6.85) | | | | 33.19 (6.93) n 90 | NS | NS
Anderson, 2001^2^ | Fat (% calories) Composites Scores mean (SD) | Intervention | 124 | 33.24 (7.28) | | | | 31.00 (6.42) n 72 | NS | NS
Anderson, 2001^2^ | Fiber (g/1,000kcals) mean (SD) | Control | NS | 9.00(3.32) | | | | 9.21(3.26) n 90 | NS | NS
Anderson, 2001^2^ | Fiber (g/1,000kcals) mean (SD) | Intervention | NS | 8.97 (2.57) | | | | 10.61 (3.37) n 72 | NS | NS
Anderson, 2001^2^ | Fruit and vegetables (servings/1000kcals) mean (SD) | Control | 136 | 2.85 (1.34) | | | | 2.5 (1.18) n 90 | NS | NS
Anderson, 2001^2^ | Fruit and vegetables (servings/1000kcals) mean (SD) | Intervention | 124 | 2.78 (1.06) | | | | 3.35 (1.56) n 72 | NS | NS
Anderson, 2001^2^ | Self Efficacy/ Low-Fat Meals mean (SD) | Control | 139 | 6.70 (1.79) | | | | 6.68 (1.73)
Anderson, 2001^2^ | Self Efficacy/ Low-Fat Meals mean (SD) | Intervention | 125 | 6.89 (1.82) | | | | 7.01 (1.67) | NS | P<.10
Anderson, 2001^2^ | Self-Efficacy/ Low-Fat Snacks mean (SD) | Control | 139 | 7.24 (1.67) | | | | 7.18 (1.61) n 132 | NS | NS
Anderson, 2001^2^ | Self-Efficacy/ Low-Fat Snacks mean (SD) | Intervention | 125 | 7.29 (1.86) | | | | 7.38 (1.80) n 98 | NS | NS
Anderson, 2001^2^ | Self-Efficacy/Fruit, Vegetables, Fiber mean (SD) | Control | 139 | 7.29 (1.78) | | | | 7.38 (1.67) n 132 | NS | NS
Anderson, 2001^2^ | Self-Efficacy/Fruit, Vegetables, Fiber mean (SD) | Intervention | 125 | 7.50 (1.58) | | | | 7.58 (1.73) n 98 | NS | NS
Anderson, 2001^2^ | Outcome Expectations/Appetite Satisfaction mean (SD) | Control | 139 | 3.92 (0.90) | | | | 3.94 (0.91) n 132 | NS | NS
Anderson, 2001^2^ | Outcome Expectations/Appetite Satisfaction mean (SD) | Intervention | 125 | 3.97 (0.93) | | | | 4.13 (0.88) n 98 | NS | P<.10
Anderson, 2001^2^ | Outcome Expectations/Budgetary Outcomes mean (SD) | Control | 139 | 3.39 (1.09) | | | | 3.40 (1.07) n 132 | NS | NS
Anderson, 2001^2^ | Outcome Expectations/Budgetary Outcomes mean (SD) | Intervention | 125 | 3.40 (1.10) | | | | 3.39 (1.14 ) n 98 | NS | NS
Anderson, 2001^2^ | Outcome Expectations/Health Outcomes mean (SD) | Control | 139 | 4.29 (0.66) | | | | 4.32 (0.63) n 132 | NS | NS
Anderson, 2001^2^ | Outcome Expectations/Health Outcomes mean (SD) | Intervention | 125 | 4.37 (0.59) | | | | 4.40 (0.58) n 98 | NS | NS
Brug, 1998^3^ | Fat (fat points per day) | General Information | 220 | 28.2 (5.2) | | | | 27.5 (5.6) | NS | NS
Brug, 1998^3^ | Fat (fat points per day) | Tailored + Iterative feedback | 215 | 28.3 (5.4) | | | | 25.6 (4.6) | NS | NS
Brug, 1998^3^ | Fat (fat points per day) | Tailored Feedback | 211 | 28.0 (5.3) | | | | 26.2 (5.2) | NS | Group effect F(2) 17. 1, p < .001
Brug, 1998^3^ | Fruit (servings per day) | General Information | 220 | 2.09 (1.75) | | | | 2.02 (1.59) | NS | NS
Brug, 1998^3^ | Fruit (servings per day) | Tailored + Iterative feedback | 215 | 2.13 (1.70) | | | | 2.45 (1.69) | NS | NS
Brug, 1998^3^ | Fruit (servings per day) | Tailored Feedback | 211 | 2.18 (1.72) | | | | 2.18 (1.47) | NS | Group effect F(2) 5.5, p < .01
Brug, 1998^3^ | Vegetables (servings per day) | General Information | 220 | 1.02 (0.36) | | | | 1.08 (0.41) | NS | NS
Brug, 1998^3^ | Vegetables (servings per day) | Tailored + Iterative feedback | 215 | 1.06 (0.38) | | | | 1.20 (0.36) | NS | NS
Brug, 1998^3^ | Vegetables (servings per day) | Tailored Feedback | 211 | 1.06 (0.41) | | | | 1.15 (0.41) | NS | Group effect F(2) 5.2, p < .01.
Brug, 1999^4^ | Fat score | Comparison | 163 | 27.4 | | | | 25.9 | NS | NS
Brug, 1999^4^ | Fat score | Experimental | 152 | 26.5 | | | | 26.2 | NS | NS
Brug, 1999^4^ | Servings of vegetables | Comparison | 163 | 1.04 | | | | 1.13 | NS | P<.01 at baseline
Brug, 1999^4^ | Servings of vegetables | Experimental | 152 | 1.14 | | | | 1.07 | NS | NS
Brug, 1999^4^ | Servings of fruit | Comparison | 163 | 1.61 | | | | 1.91 | NS | NS
Brug, 1999^4^ | Servings of fruit | Experimental | 152 | 1.62 | | | | 2.02 | NS | NS
Brug, 1999^4^ | Intention to reduce fat (Range: 23 (very surely not) to 13 (very sure). | Comparison | 163 | .11 | | | | .50 | NS | NS
Brug, 1999^4^ | Intention to reduce fat (Range: 23 (very surely not) to 13 (very sure). | Experimental | 152 | .26 | | | | .37 | NS | NS
Brug, 1999^4^ | Intention to increase vegetables Range: 23 (very surely not) to 13 (very sure). | Comparison | 163 | −.91 | | | | −.47 | NS | NS
Brug, 1999^4^ | Intention to increase vegetables Range: 23 (very surely not) to 13 (very sure). | Experimental | 152 | −1.21 | | | | −.51 | NS | NS
Brug, 1999^4^ | Intention to increase fruit dRange: 23 (very surely not) to 13 (very sure). | Comparison | 163 | −0.40 | | | | −0.13 | NS | NS
Brug, 1999^4^ | Intention to increase fruit dRange: 23 (very surely not) to 13 (very sure). | Experimental | 152 | −0.31 | | | | −0.17 | NS | NS
Campbell, 1994^5^ | Fat (g/day)Mean (SE) | no message | NS | 41,1 (2,1) | | | | 39,8(1,9) | NS | NS
Campbell, 1994^5^ | Fat (g/day)Mean (SE) | tailored message | NS | 45,6 (2,6) | | | | 35,3(1,7) | NS | 33
Campbell, 1994^5^ | Fat (g/day)Mean (SE) | Non tailored message | NS | 40,4 (2,4) | | | | 36,8(1,7) | NS | 157
Campbell, 1994^5^ | Saturated Fat (g/day) Mean (SE) | no message | NS | 16,3 (,98) | | | | 15.8 (,81) | NS | NS
Campbell, 1994^5^ | Saturated Fat (g/day) Mean (SE) | tailored message | NS | 18,7(1,1) | | | | 13,9 (.72) | NS | ,036
Campbell, 1994^5^ | Saturated Fat (g/day) Mean (SE) | Non tailored message | NS | 16,1 (.93) | | | | 14.4 (.72) | NS | ,110
Campbell, 1994^5^ | Vegetable/Fruit (servings/day) Mean (SE) | no message | NS | 3,6 (.20) | | | | 3.3 (.20) | NS | NS
Campbell, 1994^5^ | Vegetable/Fruit (servings/day) Mean (SE) | tailored message | NS | 3,6 (.19) | | | | 3,3 (,19) | NS | 0.817
Campbell, 1994^5^ | Vegetable/Fruit (servings/day) Mean (SE) | Non tailored message | NS | 3,6 (.20) | | | | 3,3 (.19) | NS | ,968
Campbell, 1994^5^ | Vegetable/Fruit (servings/day) Mean (SE) | Computer-tailored intervention | NS | 40.7 ± 14.4 | | | | 31.6 ± 12.4 | NS | NS
Campbell, 1994^5^ | Vegetable/Fruit (servings/day) Mean (SE) | Standard intervention | NS | 35.6 ± 14.2 | | | | 33.3 ± 12.9 | NS | NS
Campbell, 1994^5^ | Total fat intake (grams/ day) a , b | No intervention | NS | 100.3 ± 39.9 | | | | 97.1 ± 40.3 | NS | NS
Campbell, 1994^5^ | Total fat intake (grams/ day) a , b | Computer-tailored intervention | NS | 109.2 ± 40.7 | | | | 85.0 ± 34.5 | NS | NS
Campbell, 1994^5^ | Total fat intake (grams/ day) a , b | Standard intervention | NS | 87.5 ± 35.9 | | | | 81.8 ± 33.3 | NS | NS
Campbell, 1999^6^ | Knowledge score of low fat foods | Control | 212 | 4.13 (0.08) N Sig | | | | 4.33 (0.08) P<0.001 | NS | NS
Campbell, 1999^6^ | Knowledge score of low fat foods | Intervention | 165 | 4.29 (0.09) N Sig | | | | 5.08 (0.09) P<0.001 | NS | NS
Campbell, 1999^6^ | Self-efficacy | Control | 212 | 3.53 (0.08) N Sig | | | | 3.83 (0.07) N Sig | NS | NS
Campbell, 1999^6^ | Self-efficacy | Intervention | 165 | 3.55 (0.09) N Sig | | | | 3.94 (0.08) N Sig | NS | NS
Campbell, 1999^6^ | Fat score (g) | Control | 212 | 101.6 (4.2) P<0.001 | | | | 65.5 (2.8) N Sig | NS | NS
Campbell, 1999^6^ | Fat score (g) | Intervention | 165 | 83.8 (4.7) P<0.001 | | | | 64.1 (3.2) N Sig | NS | NS
Campbell, 1999^6^ | Stage of change- Precontemplation n (%) | Control | 212 | 31 (14.6) | | | | 18 (8.5) | −6.6 | P <0.01 for baseline difference in stage of change between study groups
Campbell, 1999^6^ | Stage of change- Precontemplation n (%) | Intervention | 165 | 14 (8.5) | | | | 9 (5.4) | −3.1 | NS
Campbell, 1999^6^ | Stage of change- Contemplation n (%) | Control | 212 | 72 (34.0) | | | | 47 (22.1) | −11.9 | NS
Campbell, 1999^6^ | Stage of change- Contemplation n (%) | Intervention | 165 | 71 (43.0) | | | | 26 (15.8) | −37.2 | NS
Campbell, 1999^6^ | Stage of change- Preparation n (%) | Control | 212 | 30 (14.2) | | | | 39 (18.3) | +4.1 | NS
Campbell, 1999^6^ | Stage of change- Preparation n (%) | Intervention | 165 | 35 (21.2) | | | | 41 (24.8) | +3.6 | NS
Campbell, 1999^6^ | Stage of change- Action/maintenance n (%) | Control | 212 | 79 (37.3) | | | | 109 (51.2) | +13.9 | NS
Campbell, 1999^6^ | Stage of change- Action/maintenance n (%) | Intervention | 165 | 45 (27.3) | | | | 89 (53.9) | +26.6 P 0.01 comparing stage progress, more people in the intervention group advanced in stage compared to the control group. | P 0.03 for difference between study groups in number of people who were in more advanced stages (preparation, action/maintenance) at follow-up, intervention . control.
Campbell, 2004^7^ | Total Low-fat knowledge score | Control-No Intervention | 166 | 1.86(1.2) | | | | 2.63 (0.55) | NS | NS
Campbell, 2004^7^ | Total Low-fat knowledge score | Computer based interactive nutrition education | 141 | 1.94(1.2) | | | | 2.76 (0.46) | NS | P ( .02).
Campbell, 2004^7^ | Total Infant feeding knowledge score | Control-No Intervention | 166 | 2.25 (0.86) | | | | 2.40 (0.75) | NS | NS
Campbell, 2004^7^ | Total Infant feeding knowledge score | Computer based interactive nutrition education | 141 | 2.29 (0.82) | | | | 2.62 (0.62)* | NS | (P < .01).
Campbell, 2004^7^ | Total self-efficacy score | Control-No Intervention | 166 | 17.08 | | | | 18.48 | NS | NS
Campbell, 2004^7^ | Total self-efficacy score | Computer based interactive nutrition education | 141 | 17.68 | | | | 18.93 (significant increase at Immediate Follow-up 19.51, P < .05 | NS | NS
Haerens, 2005^8^ | Fat intake (g day21) | control condition | (n 655 pupils) | 108 ± 46 | | | | 104 ± 45 | NS | NS
Haerens, 2005^8^ | Fat intake (g day21) | intervention with parental support | (n 1055 pupils) | 111 ± 48 | | | | 105 ± 49 | NS | NS
Haerens, 2005^8^ | Fat intake (g day21) | intervention alone | (n 685 pupils) | 130 ± 54 | | | | 127 ± 56 | NS | NS
Haerens, 2005^8^ | Fruit intake (pieces week) | control condition | (n 655 pupils) | 6.5 ± 5.0 | | | | 6.0± 4.9 | NS | NS
Haerens, 2005^8^ | Fruit intake (pieces week) | intervention with parental support | (n 1055 pupils) | 5.3 ± 5.3 | | | | 5.4 ± 5.3 | NS | NS
Haerens, 2005^8^ | Fruit intake (pieces week) | intervention alone | (n 685 pupils) | 4.6 ±5.0 | | | | 4.4 ± 4.7 | NS | NS
Haerens, 2005^8^ | Soft drinks (glasses day) | control condition | (n 655 pupils) | 2.5 ± 2.2 | | | | 2.6± 2.4 | NS | NS
Haerens, 2005^8^ | Soft drinks (glasses day) | intervention with parental support | (n 1055 pupils) | 3.1± 2.4 | | | | 3.1 ±2.5 | NS | NS
Haerens, 2005^8^ | Soft drinks (glasses day) | intervention alone | (n 685 pupils) | 3.5 ± 2.5 | | | | 3.9 ± 2.8 | NS | NS
Haerens, 2005^8^ | Water (glasses day21) | control condition | (n 655 pupils) | 3.7 ± 2.6 | | | | 4.0 ±2.8 | NS | NS
Haerens, 2005^8^ | Water (glasses day21) | intervention with parental support | (n 1055 pupils) | 3.4 ± 2.7 | | | | 3.7 ± 2.8 | NS | NS
Haerens, 2005^8^ | Water (glasses day21) | intervention alone | (n 685 pupils) | 3.1 ± 2.7 | | | | 3.5 ± 2.9 | NS | NS
Haerens, 2005^8^ | Pre- and post-test intake levels (mean ^ SD) for fat intake in girls | control condition | (n 392 pupils) | 99 ± 39 | | | | 95 ± 40 | NS | <0.001
Haerens, 2005^8^ | Pre- and post-test intake levels (mean ^ SD) for fat intake in girls | intervention with parental support | (n 432 pupils) | 97 ± 38 | | | | 85 ± 35 | NS | <.0001
Haerens, 2005^8^ | Pre- and post-test intake levels (mean ^ SD) for fat intake in girls | intervention alone | (n 108 pupils) | 108 ± 46 | | | | 98 ± 40 | NS | <0.05
Haerens, 2005^8^ | Pre- and post-test intake levels (mean ^ SD) for % energy from fat in girls | control condition | (n 392 pupils) | 38.7 ± 15.8 | | | | 36.1 ± 15.5 | NS | <0.001
Haerens, 2005^8^ | Pre- and post-test intake levels (mean ^ SD) for % energy from fat in girls | intervention with parental support | (n 432 pupils) | 37.5 ± 15.0 | | | | 31.9 ± 13.6 | NS | <.0001
Haerens, 2005^8^ | Pre- and post-test intake levels (mean ^ SD) for % energy from fat in girls | intervention alone | (n 108 pupils) | 41.1 ± 16.8 | | | | 36.6 ± 15.2 | NS | <0.05
Haerens, 2007^9^ | Dietary fat intake (self-report) (g/day) | Control | 84 | Mean, 110 SD, 42.2 | | | | 3 months after 50 minute intervention: mean, 107.3 SD, 41.5 | | NR
Haerens, 2007^9^ | Dietary fat intake (self-report) (g/day) | Intervention | 90 | Mean, 120.9 SD, 48.7 | | | | 3 months after 50 minute intervention: mean, 108.2 SD, 43.9
Haerens, 2007^9^ | Dietary fat intake (self-report) (g/day) | Intervention students who had read the intervention message | 65 | Mean, 118.4 SD, 50.1 | | | | 3 months after 50 minute intervention: mean, 102 SD, 43.8
Haerens, 2007^9^ | Dietary fat intake (technical-vocational) | Control | 67 | Mean, 118.8 SD, 50.8 | | | | 3 months after 50 minute intervention mean, 110.5 SD, 47 | | NR
Haerens, 2007^9^ | Dietary fat intake (technical-vocational) | Intervention | 63 | Mean, 109.7 SD, 51.6 | | | | 3 months after 50 minute intervention mean, 99.6 SD, 51.3
Haerens, 2007^9^ | Dietary fat intake (technical-vocational) | Intervention students who had read the intervention message | 46 | Mean, 97.8 SD, 38.9 | | | | 3 months after 50 minute intervention mean, 86.2 SD, 39.3
Haerens, 2009^10^ | Cycling for transportation | Generic Feedback | 543 | 76 (112) | | | | 105 (140) | NS
Haerens, 2009^10^ | Cycling for transportation | Tailored feedback | 511 | 78 (111) | | | | 110 (153) | NS
Haerens, 2009^10^ | Walking for transportation | Generic Feedback | 543 | 75 (120) | | | | 98 (155) | NS
Haerens, 2009^10^ | Walking for transportation | Tailored feedback | 511 | 68 (119) | | | | 95 (170) | NS
Haerens, 2009^10^ | Walking in leisure time | Generic Feedback | 543 | 42 (96) | | | | 60 (139) | NS
Haerens, 2009^10^ | Walking in leisure time | Tailored feedback | 511 | 38 (99) | | | | 61 (156) | NS
Haerens, 2009^10^ | Total moderate to vigorous activity | Generic Feedback | 543 | 618 (527) | | | | 642 (573) | NS
Haerens, 2009^10^ | Total moderate to vigorous activity | Tailored feedback | 511 | 604 (482) | | | | 642 (598) | NS
Hurling, 2006^11^ | Hypothesis 1: %of participants logging into system after 10 week test period | Control | 22 | At 3 weeks 70 | | | | At 10 weeks 43 | NS | NS
Hurling, 2006^11^ | Hypothesis 1: %of participants logging into system after 10 week test period | Intervention | 25 | At 3 weeks 70 | | | | At 10 weeks 75 | NS | NS
Hurling, 2006^11^ | Hypothesis 2: change in perception of exercise as boring; Too much effort | Control | 22 | NS | | | | NS | NS | NS
Hurling, 2006^11^ | Hypothesis 2: change in perception of exercise as boring; Too much effort | Intervention | 25 | NS | | | | F(2, 57) 3.19; F(2, 57) 2.26, | NS | p < 0.05; p=1.0.
Hurling, 2006^11^ | Hypothesis 3: Change in ratings of Expectation; satisfaction with motivation to exercise; | Control | 22 | NS | | | | 0.6; .38 | NS | p < 0.05; p <.01
Hurling, 2006^11^ | Hypothesis 3: Change in ratings of Expectation; satisfaction with motivation to exercise; | Intervention | 25 | Not clear | | | | 3.13; 3.6 | NS | p < 0.05; p <.01
Hurling, 2006^11^ | The mean change (from the beginning of the study period to 7 months after the 10-week intervention) in ratings of the statement ‘‘I am very satisfied with my current level of motivation to do exercise’’ | Control | 22 | NS | | | | −0.05 | NS | (SE 0.37)
Hurling, 2006^11^ | | Intervention | 25 | NS | | | | +0.64 | NS | (SE 0.39)
Hurling, 2007^12^ | MET min/week | Control | 30 | | | | | 9 weeks: mean, 4.0 SD, 4.1
Hurling, 2007^12^ | MET min/week | Had access to the internet and mobile phone | 47 | | | | | 9 weeks: mean, 12 SD, 3.1 | | 0.12
Hurling, 2007^12^ | Change in weekly hours spent sitting (Met min/week leisure time) | Control | 30 | | 3 weeks | | | 9 weeks mean, −5.5 SD, 3.5
Hurling, 2007^12^ | Change in weekly hours spent sitting (Met min/week leisure time) | Had access to internet and mobile phone | 47 | | 3 weeks | | | 9 weeks mean, 4.1 SD, 2.6 | | 0.03
King, 2006^13^ | Total PA (kcals/kg/hr) M (SD) | generic health risk appraisal CD-ROM | 161 | 55.5 (31.7) | | | | 53.6 (27.6) | NS | .005
King, 2006^13^ | Total PA (kcals/kg/hr) M (SD) | Interactive CD-ROM | 174 | 58.4 (33.7) | | | | 64.6 (39.1) | NS | .005
King, 2006^13^ | Moderate PA (kcals/kg/hr) M (SD) | generic health risk appraisal CD-ROM | 161 | 15.7 (19.1) | | | | 14.9 (17.8) | NS | .001
King, 2006^13^ | Moderate PA (kcals/kg/hr) M (SD) | Interactive CD-ROM | 174 | 17.2 (20.6) | | | | 22.9 (26.4) | NS | .001
Kristal, 2000^14^ | Fat-related diet habit | Control | 604 | 2.30 ± 0.49 | | | | −0.00 ± 0.40 | NS | NS
Kristal, 2000^14^ | Fat-related diet habit | Intervention | 601 | 2.29 ± 0.49 | | | | −0.09 ± 0.38 | NS | NS
Kristal, 2000^14^ | Fruit and vegetables (svg/day) | Control | 604 | 3.47 ± 1.41 | | | | 0.14 ± 1.80 | NS | NS
Kristal, 2000^14^ | Fruit and vegetables (svg/day) | Intervention | 601 | 3.62 ± 1.49 | | | | 0.47 ± 1.83 | NS | NS
Lewis, 2008^15^ | median number of logins | Standard Internet | NS | NS | | | | 38 | NS | <.05
Lewis, 2008^15^ | median number of logins | Motivationally-Tailored Internet | NS | NS | | | | 50 | NS | <.05
Lewis, 2008^15^ | 5-itemWebsite Quality Questionnaire | Standard Internet | NS | NS | | | | 11.64 | NS | <.001
Lewis, 2008^15^ | 5-itemWebsite Quality Questionnaire | Motivationally-Tailored Internet | NS | NS | | | | 16.76 | NS | <.001
Low, 2006^16^ | Eating Disorder Inventory (EDI) -Drive for Thinness | Control | 14 | Mean, 4.0 SD, 5.6 | Post Intervention: mean,5.0 SD,4.6 | | | 8–9 month follow-up: mean, 5.5 SD, 5.7
Low, 2006^16^ | Eating Disorder Inventory (EDI) -Drive for Thinness | Student bodies with a moderated discussion group | 14 | Mean, 2.5 SD, 6 | Post Intervention: mean,2.0 SD,2.0 | | | 8–9 month follow-up: mean, 2.3 SD, 5.6 | | NR
Low, 2006^16^ | Eating Disorder Inventory (EDI) -Drive for Thinness | Un-moderated discussion group | 19 | Mean, 2.3 SD, 3.4 | Post Intervention: mean,2.3 SD,2.3 | | | 8–9 month follow-up: median, 1.2; SD, 1.5
Low, 2006^16^ | Eating Disorder Inventory (EDI) -Drive for Thinness | Program alone | 14 | Mean, 4 SD, 5 | Post Intervention: mean,3.7 SD,3.6 | | | 8–9 month follow-up: mean, 3.7 SD, 4.6
Low, 2006^16^ | EDI- Bulimia | Control | 14 | Mean, 1.2 SD, 1.6 | Post Intervention: mean,1.1 SD, 1.0 | | | 8–9 month follow-up mean, 2 SD, 1.9
Low, 2006^16^ | EDI- Bulimia | Student bodies with a moderated discussion group | 14 | Mean, 1.4 SD, 4.2 | Post Intervention: mean,1.7 SD, 1.7 | | | 8–9 month follow-up mean, 0.46 SD, 1.9 | | p<0.05 for pair wise comparison
Low, 2006^16^ | EDI- Bulimia | Un-moderated discussion group | 19 | Mean, 1.4 SD, 2.2 | Post Intervention: mean,0.85 SD, 0.86 | | | 8–9 month follow-up mean, 0.42 SD, 0.84 | | p<0.05 for pair wise comparison
Low, 2006^16^ | EDI- Bulimia | Program alone | 14 | Mean, 1.2 SD, 1.5 | Post Intervention: mean,0.47 SD, 0.53 | | | 8–9 month follow-up mean, 1.3 SD, 1.6
Low, 2006^16^ | EDI-Body Dissatisfaction | Control | 14 | Mean, 9.4 SD, 8 | Post Intervention: mean,7.9 SD, 8.2 | | | 8–9 month follow-up mean, 9.4 SD, 7.8 | | p<0.05 for pair wise comparison
Low, 2006^16^ | EDI-Body Dissatisfaction | Student bodies with a moderated discussion group | 14 | Mean, 8.1 SD, 6.8 | Post Intervention: mean,7.6 SD, 7.6 | | | 8–9 month follow-up mean, 7 SD, 4.9
Low, 2006^16^ | EDI-Body Dissatisfaction | Un-moderated discussion group | 19 | Mean, 7.9 SD, 6.4 | Post Intervention: mean, 5.9 SD, 5.9 | | | 8–9 month follow-up mean, 5.2 SD, 4.2 | | p<0.05 for pair wise comparison
Low, 2006^16^ | EDI-Body Dissatisfaction | Program alone | 14 | Mean, 9 SD, 6.7 | Post Intervention: mean,7.1 SD, 7.1 | | | 8–9 month follow-up mean, 6.3 SD, 7.8
Low, 2006^16^ | Weight and Shape Concerns | Control | 14 | Mean, 37 SD, 22.3 | Post Intervention: mean,41.8 SD, 22.8 | | | 8–9 month follow-up mean, 43.2 SD, 21.1 | | p<0.05 for pair wise comparison
Low, 2006^16^ | Weight and Shape Concerns | Student bodies with a moderated discussion group | 14 | Mean, 33.8 SD, 22.4 | Post Intervention: mean, 32.2 SD, 33.8 | | | 8–9 month follow-up mean, 29.9 SD, 23.1
Low, 2006^16^ | Weight and Shape Concerns | Un-moderated discussion group | 19 | Mean, 29.5 SD, 16.6 | Post Intervention: mean, 28.5 SD, 29.3 | | | 8–9 month follow-up mean, 27.5 SD, 14.5 | | p<0.05 for pair wise comparison
Low, 2006^16^ | Weight and Shape Concerns | Program alone | 14 | Mean, 38.3 SD,17.0 | Post Intervention: mean, 38.2 SD, 26.7 | | | 8–9 month follow-up mean, 34.6 SD, 16.7
Mangunkusumo, 2007^17^ | Evaluation of Health Behavior mode (easy to use) (Likert Scale) | Control | 465 | | | | | 2–4 months: mean, 4.1; median, 4; range, 4.0–5.0; SD, 0.7 | | 0.035
Mangunkusumo, 2007^17^ | Evaluation of Health Behavior mode (easy to use) (Likert Scale) | Internet Group | 444 | | | | | 2–4 months: mean, 4.2; median, 4.0 ; range, 4.0–5.0; SD, 0.7 | | 0.035
Mangunkusumo, 2007^17^ | Evaluation of Fruit Advice (pleasant) (Likert Scale | Control | 418 | | | | | 2–4 months mean, 3.7 median, 4 range, 3.0–4.0 SD, 0.7 | | 0.005
Mangunkusumo, 2007^17^ | Evaluation of Fruit Advice (pleasant) (Likert Scale | Internet | 381 | | | | | 2–4 months mean, 3.8 median, 4 range, 3.0–4.0 SD, 0.7 | | 0.005
Mangunkusumo, 2007^17^ | Acceptability (Was fruit advice targeted to you?) | Control | 417 | | | | | 2–4 months mean, 3.3 median, 3 range, 3.0–4.0 SD, 1 | | 0.001
Mangunkusumo, 2007^17^ | Acceptability (Was fruit advice targeted to you?) | Internet Group | 376 | | | | | 2–4 months mean, 3.5 median, 4 range, 3.0–4.0 SD, 0.9 | | 0.001
Mangunkusumo, 2007^17^ | Acceptability (Did you enjoy it) | Control | 417 | | | | | 2–4 months mean, 3.2 median, 3 range, 3.0–4.0 SD, 1 | | 0.004
Mangunkusumo, 2007^17^ | Acceptability (Did you enjoy it) | Internet Group | 376 | | | | | 2–4 months mean, 3.4 median, 4 range, 3.0–4.0 SD, 0.9 | | BL, 0.004 time point 2, Liker Scale 1–5
Mangunkusumo, 2007^17^ | Quality of Intervention (relevant) | Control | 417 | | | | | 2–4 months: mean, 3.3: median, 4: range, 3.0–4.0: SD, 1 | | 0.49
Mangunkusumo, 2007^17^ | Quality of Intervention (relevant) | Internet Group | 376 | | | | | 2–4 months: mean, 3.5: median, 4: range, 3.0–4.0: SD, 1 | | 0.49
Mangunkusumo, 2007^17^ | Quality of Intervention (credible) | Control | 417 | | | | | 2–4 months mean, 3.8 median, 4 range, 4.0-4.0 SD, 0.8 | | 0.003
Mangunkusumo, 2007^17^ | Quality of Intervention (credible) | Internet Group | 376 | | | | | 2–4 months mean, 3.6 median, 4 range, 3.0–4.0 SD, 0.9 | | 0.003
Mangunkusumo, 2007^17^ | Quality of Intervention (useful) | Control | 417 | | | | | 2–4 months mean, 3.7 median, 4 range, 3.0–4.0 SD, 0.9 | | 0.048
Mangunkusumo, 2007^17^ | Quality of Intervention (useful) | Internet | 376 | | | | | 2–4 months mean, 3.6 median, 4 range, 3.0–4.0 SD, 0.9 | | 0.048
Marcus, 2007^18^ | Physical activity per week | Tailored print | 86 | Minutes of physical activity per week (using PAR interview) | 6 months mean, 112.5 | | | 12 months: mean, 90 | | Time point 2, 0.15 final time point, 0.74
Marcus, 2007^18^ | | Tailored internet | 81 | Minutes of physical activity per week (using PAR interview) | 6 months mean, 120 | | | 12 months: mean, 90 | | Time point 2, 0.15 final time point, 0.74
Marcus, 2007^18^ | | Standard internet | 82 | Minutes of physical activity per week (using PAR interview) | 6 months mean, 90 | | | 12 months mean, 80 | | Time point 2, 0.15 final time point, 0.74
Marcus, 2007^18^ | Improvement in functional capacity (estimated v02 at 85% of predicted maximum heart rate) (ml/kg per minute) | Tailored print | 86 | | 6 months mean, 25.8 SD, 6.8 | | | 12 months mean, 26.2 SD, 6.9 | | Time point 2, >.99 final time point, 0.31
Marcus, 2007^18^ | | Tailored internet | 81 | | 6 months mean, 26.5 SD, 6.6 | | | 12 months mean, 26.1 SD, 6.9 | | Time point 2, >.99 final time point, 0.31
Marcus, 2007^18^ | | Standard internet | 82 | | 6 months mean, 25.4 SD, 6.6 | | | 12 months mean, 25.7 SD, 6 | | Time point 2, >.99 final time point, 0.31
Marcus, 2007^18^ | 150 minutes of physical activity per week (150 minutes) | Tailored print | 86 | | 6 months, (37.2) | | | 12 months, (32.6) | | Time point 2, 0.52 final time point, 0.45
Marcus, 2007^18^ | | Tailored internet | 81 | | 6 months, (44.4) | | | 12 months, (39.5) | | Time point 2, 0.52 final time point, 0.45
Marcus, 2007^18^ | | Standard internet | 82 | | 6 month, (36.6) | | | 12 months, (30.5) | | Time point 2, 0.52 Final time point, 0.45
Napolitano, 2003^19^ | Minutes moderate physical activity | Control | 31 | Mean, 80.86 SD, 77.8 | 1 month mean, 96.82 SD, 93.7 | | | 3 month: mean, 82 SD, 87.3
Napolitano, 2003^19^ | Minutes moderate physical activity | Internet intervention | 21 | Mean, 68.79 SD, 58.1 | 1 month mean, 98.33 SD, 53.9 | | | 3 month: mean, 112 SD, 75.7 | | P<0.05 at one month, NS at 3 months
Napolitano, 2003^19^ | Minutes, walking | Control | 31 | Mean, 87.57 SD, 177.4 | 1 month mean, 83.79 SD, 121.1 | | | 3 month mean, 68.39 SD, 85.2
Napolitano, 2003^19^ | Minutes, walking | Internet intervention | 21 | Mean, 57.24 SD, 56.9 | 1 month mean, 87.29 SD, 46 | | | 3 month mean, 99.75 SD, 68.3 | | p<0.001 at one month and p<0.05 at three months
Napolitano, 2003^19^ | Stage of change, progression | Control | 31 | | 1 month | | | 3 month
Napolitano, 2003^19^ | Stage of change, progression | Internet intervention | 21 | | 1 month | | | 3 month | | p<0.05) at one month and p<0.01 at three months
Oenema, 2001^20^ | Intention to eat less fat | Control | 102 | | | | | Post-intervention: mean, 0.29 SD, 1.26 | | Diff between intervention and control at post test, p<0.01
Oenema, 2001^20^ | Intention to eat less fat | Web based tailored nutrition education | 96 | | | | | Post-intervention: mean, 0.72 SD, 1.21 | | Diff between intervention and control at post test, p<0.01
Oenema, 2001^20^ | Self-rated fat intake compared to others | Control | 102 | Mean, −0.44 SD, 0.77 | | | | Post-intervention mean, −0.33 SD, 0.74 | | Diff between intervention and control at post test, p<0.01
Oenema, 2001^20^ | Self-rated fat intake compared to others | Web based tailored nutrition education | 96 | Mean, −0.31 SD, 0.7 | | | | Post-intervention mean, −0.05 SD, 0.8 | | Diff between intervention and control at post test, p<0.01
Oenema, 2001^20^ | Self-rated fruit intake | Control | 102 | Mean, −0.51 SD, 0.98 | | | | Post-intervention mean, −0.49 SD, 0.97 | | Diff between intervention and control at post test, p<0.01
Oenema, 2001^20^ | Self-rated fruit intake | Web based tailored nutrition education | 96 | Mean, −0.49 SD, 0.91 | | | | Post-intervention mean, −0.27 SD, 0.93 | | Diff between intervention and control at post test, p<0.01
Oenema, 2001^20^ | Self rated fat intake | Control | 102 | Mean, −0.23 SD, 0.77 | | | | Post-intervention mean, 0.01 SD, 0.81 | | Diff between intervention and control at post test, p<0.05
Oenema, 2001^20^ | Self rated fat intake | Tailored | 96 | Mean, 0.03 SD, 0.73 | | | | Post-intervention mean, 0.17 SD, 0.68 | | Diff between intervention and control at post test, p<0.05
Oenema, 2001^20^ | Self rated fruit intake compared to others | Control | 102 | Mean, −0.34 SD, 1.01 | | | | Post-intervention: mean, −0.34 SD, 0.96 | | Diff between intervention and control at post test, p<0.05
Oenema, 2001^20^ | Self rated fruit intake compared to others | Tailored | 96 | Mean, −0.31 SD, 0.93 | | | | Post-intervention: mean, −0.16 SD, 0.89 | | Diff between intervention and control at post test, p<0.05
Oenema, 2001^20^ | Self-rated vegetable intake | Control | 102 | Mean, 0.37 SD, 0.73 | | | | Post-intervention mean, 0.3 SD, 0.76 | | NS
Oenema, 2001^20^ | Self-rated vegetable intake | Tailored | 96 | Mean, 0.2 SD, 0.71 | | | | Post-intervention mean, 0.08 SD, 0.74 | | NS
Oenema, 2001^20^ | Self-rated vegetable intake compared to other | Control | 102 | Mean, 0.3 SD, 0.78 | | | | Post-intervention mean, 0.27 SD, 0.72 | | NS
Oenema, 2001^20^ | Self-rated vegetable intake compared to other | Tailored | 96 | Mean, 0.18 SD, 0.74 | | | | Post-intervention mean, 0.08 SD, 0.82 | | NS
Oenema, 2005^21^ | Fat intake | Control | 232 | Mean, 20.3 SD, 6.2 | | | | 3 weeks after sending intervention materials: mean, 19.9 SD, 6.2
Oenema, 2005^21^ | | General information | 196 | Mean, 20.0 SD, 5.9 | | | | 3 weeks after sending intervention materials: mean, 19.2 SD, 6.0
Oenema, 2005^21^ | | Tailored Information | 188 | Mean, 19.8 SD, 6.1 | | | | 3 weeks after sending intervention materials: mean, 19.2 SD, 6.2
Oenema, 2005^21^ | Vegetable intake | Control | 232 | Mean, 1.9 SD, 1.0 | | | | 3 weeks after sending intervention materials mean, 1.8 SD, 0.9
Oenema, 2005^21^ | | General information | 196 | Mean, 1.8 SD, 0.8 | | | | 3 weeks after sending intervention materials Mean,1.7 SD,0.8
Oenema, 2005^21^ | | Tailored Information | 188 | Mean, 1.8 SD, 0.8 | | | | 3 weeks after sending intervention materials mean, 1.9 SD, 0.9
Oenema, 2005^21^ | Fruit intake | Control | 232 | Mean, 2.1 SD, 1.4 | | | | 3 weeks after sending intervention materials mean, median, 2.0 range, SD, 1.6
Oenema, 2005^21^ | | General information | 196 | Mean, 2.1 SD, 1.4 | | | | 3 weeks after sending intervention materials mean, 2.0 SD, 1.2
Oenema, 2005^21^ | | Tailored intervention | 188 | Mean, 2.2 SD, 1.6 | | | | 3 weeks after sending intervention materials mean, 2.3 SD, 1.6
Oenema, 2005^21^ | Fat self-rated intake | Control | 232 | Mean, −0.11 SD, 0.81 | | | | 3 weeks after sending intervention materials mean, −0.18 SD, 0.73
Oenema, 2005^21^ | | General | 196 | Mean, −.16 SD, 0.70 | | | | 3 weeks after sending intervention materials mean, −0.22 SD, 0.71
Oenema, 2005^21^ | | Tailored | 188 | Mean, −0.25 SD,0.68 | | | | 3 weeks after sending intervention materials mean, −0.12 SD, 0.76
Oenema, 2005^21^ | Vegetable self-rated intake | Control | 232 | Mean, 0.42 SD, 0.71 | | | | 3 weeks after sending intervention materials: mean, 0.37 SD, 0.70
Oenema, 2005^21^ | | General information | 196 | Mean, 0.44 SD, 0.68 | | | | 3 weeks after sending intervention materials: mean, 0.37 SD, 0.71
Oenema, 2005^21^ | | Tailored | 188 | Mean, 0..35 SD, 0.67 | | | | 3 weeks after sending intervention materials: mean, 0.16 SD, 0.69
Oenema, 2005^21^ | Fruit self-rated intake | Control | 232 | Mean, −0.22 SD, 0.99 | | | | 3 weeks after sending intervention materials mean, −0.26 SD, 0.91
Oenema, 2005^21^ | | General information | 196 | Mean, −0.26 SD, 0.95 | | | | 3 weeks after sending intervention materials mean, −0.16 SD, 0.89
Oenema, 2005^21^ | | Tailored intervention | 188 | Mean, −0.19 SD, 1.09 | | | | 3 weeks after sending intervention materials mean, −0.19 SD, 1.05
Oenema, 2005^21^ | Fat Intention to Change | Control | 232 | Mean, −0.21 SD, 1.01 | | | | 3 weeks after sending intervention materials mean, −0.24 SD, 1.00
Oenema, 2005^21^ | | General | 196 | Mean, −0.13 SD, 0.95 | | | | 3 weeks after sending intervention materials mean, −0.13 SD, 0.99
Oenema, 2005^21^ | | Tailored | 188 | Mean, −0.23 SD, 0.92 | | | | 3 weeks after sending intervention materials mean, 0.01 SD, 0.97
Oenema, 2005^21^ | Vegetable Intention to Change | Control | 232 | Mean, 0.85 SD, −0.31 | | | | 3 weeks after sending intervention materials: mean, −0.26 SD, 0.89
Oenema, 2005^21^ | | General | 196 | Mean, −0.32 SD, 0.83 | | | | 3 weeks after sending intervention materials: mean, −0.25 SD, 0.81
Oenema, 2005^21^ | | Tailored | 188 | Mean, −0.38 SD, 0.78 | | | | 3 weeks after sending intervention materials: mean, −0.04 SD, 0.93
Oenema, 2005^21^ | Fruit Intention to Change | Control | 232 | Mean, −0.08 SD,0.93 | | | | 3 weeks after sending intervention materials: mean, −0.13 SD, 0.85
Oenema, 2005^21^ | | General | 196 | Mean,0.02 SD,0.90 | | | | 3 weeks after sending intervention materials: mean, −0.04 SD,0.92
Oenema, 2005^21^ | | Tailored | 188 | Mean, −0.10 SD,0.88 | | | | 3 weeks after sending intervention materials: mean, −0.01 SD,1.01
Richardson, 2007^22^ | Total Steps | LG | 17 | 4,157 ± 1,737 | | | | 6,279 ± 3,306 | | 0.0142
Richardson, 2007^22^ | Total Steps | SG | 13 | 5,171 ± 1,769 | | | | 6,868 ± 3,751 | | 0.1117
Richardson, 2007^22^ | Bout Steps | LG | 17 | 286 ± 599 | | | | 2,070 ± 2,814 | | 0.0164*
Richardson, 2007^22^ | Bout Steps | SG | 13 | 516 ± 801 | | | | 2,616 ± 2,706 | | 0.0196*
Richardson, 2007^22^ | Change | LG | 17 | | | | | 2,122 ± 3,179
Richardson, 2007^22^ | Change | SG | 13 | | | | | 1,783 ± 2,741
Smeets, 2007^23^ | Fat consumption (gm) | Control | 1410 | Mean, 18.7 SD, 6.2 | | | | Post test at 3 month: mean, −1 SD, 0.05 | | 0.01
Smeets, 2007^23^ | Fat consumption (gm) | Intervention group, receiving one tailored letter | 1417 | Mean, 18.7 SD, 6.2 | | | | Post test at 3 month: mean, −2.5 SD, −0.05 | | 0.05
Smeets, 2007^23^ | Fruit consumption (pieces/day) | Control | 1410 | Mean, 2.7 SD, 1.7 | | | | Post test at 3 month mean, −0.2 SD, 0.06 | | 0.01
Smeets, 2007^23^ | Fruit consumption (pieces/day) | Intervention group, receiving one tailored letter | 1417 | Mean, 2.7 SD, 1.7 | | | | Post test at 3 month mean, 0.04 SD, 0.06 | | 0.01
Smeets, 2007^23^ | Vegetable consumption (gm/day) | Control | 1410 | Mean, 139 SD, 140 | | | | Post test at 3 month mean, −10.4 | | NR
Smeets, 2007^23^ | Vegetable consumption (gm/day) | Intervention group, receiving one tailored letter | 1417 | Mean, 139 SD 140 | | | | Post test at 3 month mean, −0.48
Smeets, 2007^23^ | Physical activity (action moments/wk) | Control | 1410 | Mean, 5 SD, 3.6 | | | | Post test at 3 month mean, −1.1
Smeets, 2007^23^ | Physical activity (action moments/wk) | Intervention group, receiving one tailored letter | 1417 | Mean, 5 SD, 3.6 | | | | Post test at 3 month mean, −0.7 | | BL, time point 2, Baseline mean and SD are for control and treatment groups together. The final time point mean and SD reflect the change in action moments per day per day (post-test minus baseline).
Spittaels, 2007^24^ | Total MVPA scores=Moderate- to vigorous-intensity physical activity for completers | No Intervention | 104 | 201 (254) | | | | 233 (273) | +32 | NS
Spittaels, 2007^24^ | Total MVPA scores=Moderate- to vigorous-intensity physical activity for completers | Website with computer tailored feedback | 103 | 292 (285) | | | | 420 (337) | +128 | NS
Spittaels, 2007^24^ | Total MVPA scores=Moderate- to vigorous-intensity physical activity for completers | Website without computer tailored feedback | 78 | 290 (319) | | | | 352 (357) | +62 | NS
Spittaels, 2007^25^ | Increase in total physical activity | Control | 141 | Mean, 622 SD, 462 | | | | 6 month: mean, 708 SD, 514
Spittaels, 2007^25^ | Increase in total physical activity | On-line tailored PA advice+ stage based reinforcement emails | 116 | Mean, 696 SD, 510 | | | | 6 month: mean, 776 SD, 540 | | 0.001
Spittaels, 2007^25^ | Increase in total physical activity | On-line tailored physical activity advice | 122 | Mean, 640 SD, 422 | | | | 6 month: mean, 682 SD, 452
Spittaels, 2007^25^ | Increase in moderate to vigorous physical activity | Control | 141 | Mean, 376 SD, 325 | | | | 6 month mean, 428 SD, 374
Spittaels, 2007^25^ | Increase in moderate to vigorous physical activity | On-line tailored PA advice+ stage based reinforcement emails | 116 | Mean, 438 SD, 373 | | | | 6 month mean, 479 SD, 376 | | 0.05
Spittaels, 2007^25^ | Increase in moderate to vigorous physical activity | On-line tailored physical activity advice only | 122 | Mean, 362 SD, 292 | | | | 6 month mean, 397 SD, 310
Spittaels, 2007^25^ | Increase in physical activity in leisure time | Control | 141 | Mean, 151 SD, 152 | | | | 6 month mean, 185 SD, 161
Spittaels, 2007^25^ | Increase in physical activity in leisure time | On-line tailored PA advice+ stage based reinforcement emails | 116 | Mean, 174 SD, 191 | | | | 6 month mean, 211 SD, 220 | | .001
Spittaels, 2007^25^ | Increase in physical activity in leisure time | On-line tailored physical activity advice only | 122 | Mean, 154 SD, 150 | | | | 6 month mean, 190 SD, 188
Tate, 2006^26^ | Dietary intake (kcal/day) | Control | 54 | Mean, 1869.7 SD, 778.9 | 3 month: mean, 1544.2 SD,651.7 | | | 6 month: mean, 1603.5 SD, 793.7
Tate, 2006^26^ | Dietary intake (kcal/day) | Tailored Computer-Automated Feedback | 40 | Mean, 1911 SD, 770.9 | 3 month: mean,1381.7 SD,448.2 | | | 6 month: mean, 1488.7 SD, 580.2 | | p<0.21 at 3 months and p<0.28 at 6 months
Tate, 2006^26^ | Dietary intake (kcal/day) | Human Email Counseling (HC) | 52 | Mean, 2042.6 SD, 875.6 | 3 month: mean,1468.2 SD,449.1 | | | 6 month: mean, 1484.3 SD, 574.3 | | p<0.21 at 3 months and p<0.28 at 6 months
Tate, 2006^26^ | Fat intake (% day) | Control | 54 | Mean, 38.4, SD, 7.1 | 3 month: mean,36.0 SD,7.0 | | | 6 month mean, 37.3 SD, 6.6
Tate, 2006^26^ | Fat intake (% day) | Tailored Computer-Automated Feedback | 40 | Mean, 37.5 SD, 6.1 | 3 month: mean,33.5 SD,4.9 | | | 6 month mean, 34 SD, 6.5 | | p<0.04 at 3 months and p<0.004 at 6 months
Tate, 2006^26^ | Fat intake (% day) | Human Email Counseling (HC) | 52 | Mean,38.8 SD, 6.2 | 3 month: mean, 32.8 SD,5.0 | | | 6 month mean, 33.1 SD,4.9 | | p<0.04 at 3 months and p<0.004 at 6 months
Tate, 2006^26^ | Physical activity (kcal/week) | Control | 54 | Mean, 1188.7 SD, 1286.8 | 3 month: mean, 1335.8 SD,1540 | | | 6 month mean, 1064.4 SD, 1139.5
Tate, 2006^26^ | Physical activity (kcal/week) | Tailored Computer-Automated Feedback | 40 | Mean, 1210.9 SD, 1234.9 | 3 month: mean,1525.1 SD,1368.9 | | | 6 month mean, 1335.1 SD, 1410.1 | | p<0.08 at 3 months and p<0.52 at 6 months
Tate, 2006^26^ | Physical activity (kcal/week) | Human Email Counseling (HC) | 52 | Mean, 1283.9 SD, 1969.3 | 3 month: mean, 1537.2 SD,1113 | | | 6 month mean, 1377.1 SD, 1163.8 | | p<0.08 at 3 months and p<0.52 at 6 months
Vandelanotte, 2005^27^ | Increase Physical activity | Control | 204 | Minutes of pa/week mean, 720 SD, 485 | | | | 6 months: mean, 734 SD, 516
Vandelanotte, 2005^27^ | Increase Physical activity | Sequential interactive computer tailored intervention | 180 | Minutes of pa/week mean, 514 SD, 367 | | | | 6 months: mean, 727 SD, 492
Vandelanotte, 2005^27^ | Increase Physical activity | Simultaneous interactive computer tailored intervention | 189 | Minutes of pa/week mean, 532 SD, 519 | | | | 6 months: mean, 705 SD, 519
Vandelanotte, 2005^27^ | Decrease fat intake | Control | 195 | Grams/week: mean, 101 SD, 39 | | | | 6 months mean, 94 SD, 33
Vandelanotte, 2005^27^ | Decrease fat intake | Sequential interactive computer tailored intervention | 194 | Gram/week: mean, 110 SD, 39 | | | | 6 months mean, 85 SD, 30
Vandelanotte, 2005^27^ | Decrease fat intake | Simultaneous interactive computer tailored intervention | 176 | Grams/week: mean, 118 SD, 43 | | | | 6 months mean, 85 SD, 28
Verheijden, 2004^28^ | Perceived support | Control | 73 | Mean score, range, 1–7, higher score, better outcome mean, 5.7 SD, 1.2 | Change after 4 month mean, −0.08 | | | Change after 8 month: mean, −0.07 SD, | | BL, 0.87 time point 2, 0.29 final time point, 0.60
Verheijden, 2004^28^ | Perceived support | Web-Based Targeted Nutrition Counseling and Social Support | 24 | Mean score, range,1–7, higher score, better outcome mean, 5.7 SD, 1.3 | Change after 4 month mean, 0.11 | | | Change after 8 month: mean, −0.17 SD, | | BL, 0.87 time point 2, 0.29 final time point, 0.60
Verheijden, 2004^28^ | Social network | Control | 73 | Mean score, range,1–7, higher score, better outcome: mean, 3.5 SD, 0.5 | Change after 4 month mean, 0.04 SD, | | | Change after 8 month mean, 0.07 SD, | | BL, 0.35 time point 2, 0.21 final time point, 0.49
Verheijden, 2004^28^ | Social network | Web-Based Targeted Nutrition Counseling and Social Support | 24 | Mean score, range,1–7, higher score, better outcome: mean, 3.5 SD, 0.5 | Change after 4 month mean, −.0.06 SD, | | | Change after 8 month mean, 0.01 SD, | | BL, 0.35 time point 2, 0.21 final time point, 0.49
Verheijden, 2004^28^ | BMI ( kg/m2) | Control | 73 | BMI, kg/m2 mean, 29.2 SD, 4.5 | Change after 4 month mean, −0.21 SD, | | | Change after 8 month mean, −0.01 SD, | | BL, 0.73 time point 2, 0.07 final time point, 0.12
Verheijden, 2004^28^ | BMI ( kg/m2) | Web-Based Targeted Nutrition Counseling and Social Support | 24 | BMI, kg/m2 mean, 29.5 SD, 5.2 | Change after 4 month mean, 0.08 SD, | | | Change after 8 month mean, −0.02 SD, | | BL, 0.73 time point 2, 0.07 final time point, 0.12
Verheijden, 2004^28^ | Systolic blood pressure | Control | 73 | Systolic blood pressure mean, 136 SD, 18 | Change after 4 month mean, −2.1 SD, | | | Change after 8 month mean, −5.2 SD, | | BL, 0.42 time point 2, 0.46, final time point, 0.16
Verheijden, 2004^28^ | Systolic blood pressure | Web-Based Targeted Nutrition Counseling and Social Support | 24 | Systolic blood pressure mean, 134 SD, 14 | Change after 4 month mean, −0.4 | | | Change after 8 month mean, −1.9 SD, | Time point 2, 0.42 time point 3, 0.46 | BL, 0.42 time point 2, 0.46 final time point, 0.16
Verheijden, 2004^28^ | Diastolic blood pressure | Control | 73 | Diastolic blood pressure: mean, 80 SD, 11 | Change after 4 month: mean, −1.4 SD, | | | Change after 8 month: mean, −3.2 SD, | | BL, 0.61 time point 2, 0.44 final time point, 0.6
Verheijden, 2004^28^ | Diastolic blood pressure | Web-Based Targeted Nutrition Counseling and Social Support | 24 | Diastolic blood pressure: mean, 81 SD, 9 | Change after 4 month: mean, −0.2 SD, | | | Change after 8 month: mean, −2.5 SD, | | BL, 0.61 time point 2, 0.44 final time point, 0.6
Verheijden, 2004^28^ | Total cholesterol | Control | 73 | Total cholesterol mean, 5.4 SD, 1.2 | Change after 4 month mean, −0.06 SD, | | | Change after 8 month mean, −0.11 SD, | | BL, 0.56 time point 2, 0.41 final time point, 0.79
Verheijden, 2004^28^ | Total cholesterol | Web-Based Targeted Nutrition Counseling and Social Support | 24 | Total cholesterol mean, 5.5 SD, 0.9 | Change after 4 month mean, 0.03 SD, | | | Change after 8 month mean, −0.08 SD, | | BL, 0.56 time point 2, 0.41 final time point, 0.79
Wylie-Rosett, J, 2001^29^ | Dietary Intake (Kcal/d) | Work book only | 97 | NS | | | | −397.9±55.3 | NS | NS
Wylie-Rosett, J, 2001^29^ | Dietary Intake (Kcal/d) | Computer tailored feedback | 183 | NS | | | | −283±41.8 | NS | NS
Wylie-Rosett, J, 2001^29^ | Dietary Intake (Kcal/d) | Computer tailored feedback plus staff consultation | 194 | NS | | | | −323.6±43.1 | NS | NS
Wylie-Rosett, J, 2001^29^ | Exercise (Blocks walked daily) | Work book only | 97 | NS | | | | 5.9±1.10 | NS | NS
Wylie-Rosett, J, 2001^29^ | Exercise (Blocks walked daily) | Computer tailored feedback | 183 | NS | | | | 5.1±0.79 | NS | NS
Wylie-Rosett, J, 2001^29^ | Exercise (Blocks walked daily) | Computer tailored feedback plus staff consultation | 194 | NS | | | | 3.9±0.79 | NS | NS
Wylie-Rosett, J, 2001^29^ | Exercise (min walked continuously) | Work book only | 97 | NS | | | | 5.10±1.10 | NS | NS
Wylie-Rosett, J, 2001^29^ | Exercise (min walked continuously) | Computer tailored feedback | 183 | NS | | | | 5.11±1.13 | NS | NS
Wylie-Rosett, J, 2001^29^ | Exercise (min walked continuously) | Computer tailored feedback plus staff consultation | 194 | NS | | | | 4.96±1.09 | NS | NS
Wylie-Rosett, J, 2001^29^ | Weight (lb) | Work book only | 97 | NS | | | | −2.2±1.26 | NS | .003
Wylie-Rosett, J, 2001^29^ | Weight (lb) | Computer tailored feedback | 183 | NS | | | | −4.7±1.02 | NS | .003
Wylie-Rosett, J, 2001^29^ | Weight (lb) | computer tailored feedback plus staff consultation | 194 | NS | | | | −7.4±1.15 | NS | .003
Wylie-Rosett, J, 2001^29^ | BMI | Work book only | 97 | NS | | | | −0.4±0.21 | NS | .003
Wylie-Rosett, J, 2001^29^ | BMI | Computer tailored feedback | 183 | NS | | | | −0.8±0.17 | NS | .003
Wylie-Rosett, J, 2001^29^ | BMI | computer tailored feedback plus staff consultation | 194 | NS | | | | −1.2±0.19 | NS | .003
Eating disorder
Winzelberg, 2000^30^ | Body shape measure | Control | 20 | Mean, 104 SD, 36 | Post Intervention mean, 107 SD, 39 | | | 3months: mean, 101 SD, 44
Winzelberg, 2000^30^ | Body shape measure | Intervention group | 24 | Mean, 118 SD, 34 | Post Intervention mean, 104 SD, 33 | | | 3months: mean, 93 SD, 25 | | p<0.01
Winzelberg, 2000^30^ | EDI-drive for thinness | Control | 20 | Mean, 24 SD, 8 | Post Intervention mean, 26 SD, 9.4 | | | 3months mean, 24.8 SD, 9.9
Winzelberg, 2000^30^ | EDI-drive for thinness | Intervention | 24 | Mean, 27.6 SD, 9.7 | Post Intervention mean, 25.1 SD, 8.8 | | | 3months mean, 23.3 SD, 9.1 | | p<.05
Winzelberg, 2000^30^ | EDI-Bulimia | Control | 20 | Mean, 14 SD, 4.9 | Post Intervention mean, 14.8 SD, 6 | | | 3months mean, 13.8 SD, 6.7
Winzelberg, 2000^30^ | EDI-Bulimia | Intervention | 24 | Mean, 15.9 SD, 8.4 | Post Intervention mean, 14.1 SD, 7 | | | 3months mean, 12.6 SD, 5.7 | | NS
Winzelberg, 2000^30^ | EDE-Q Weight Concerns | Control | 20 | Mean, 2.5 SD, 1.3 | Post Intervention mean, 2.7 SD, 1.6 | | | 3months mean, 2.5 SD, 1.6
Winzelberg, 2000^30^ | EDE-Q Weight Concerns | Intervention | 24 | Mean, 2.8 SD, 1.4 | Post Intervention mean,2.5 SD,1.3 | | | 3months mean, median, 2.3 range, SD, 1.2 | | NS
Winzelberg, 2000^30^ | EDE-Q Shape Concern | Control | 20 | Mean, 2.7 SD, 1.5 | Post Intervention: mean, 3 SD, 1.6 | | | 3months: mean, 2.6 SD, 1.7
Winzelberg, 2000^30^ | EDE-Q Shape Concern | Intervention | 24 | Mean, 3.3 SD, 1.4 | Post Intervention: mean, 2.8 SD, 1.3 | | | 3months: mean, 2.5 SD, 1.3 | | NS
Nutrition intervention
Bruge, 1996^31^ | Fat (points per day) | Control | 169 | Fat points/ day mean, 28 SD, 5.3 | | | | 3 weeks after receiving nutrition letter: mean, 27.2 SD, 5.5 | | p<0.05 for diff between baseline and post test
| | Tailored feedback | 178 | Fat points/ day mean, 29 SD, 5 | | | | 3 weeks after receiving nutrition letter: mean, 26.9 SD, 4.9 | | p<.01 between baseline and post-test; p<.01 for diff between tailored and control group
| Vegetables (servings per day) | Control | 169 | Servings/day: mean, 1 SD, 0.31 | | | | 3 weeks after receiving nutrition letter mean, 1.06 SD, 0.37 | | p<0.05 for diff between baseline and post test
| | Tailored feedback | 178 | Mean, 1.03 SD, 0.36 | | | | 3 weeks after receiving nutrition letter mean, 1.07 SD, 0.36 | | NS
| Fruit (servings per day) | Control | 169 | Servings/ day mean, 1.61 SD, 1.14 | | | | 3 weeks after receiving nutrition letter mean, 1.57 SD, 1.19 | | None
| | | 178 | Servings/ day mean, 1.49 SD, 1 | | | | 3 weeks after receiving nutrition letter mean, 1.57 SD, 0.96 | | None
| Positive attitude to increasing vegetables and fruits | Control | 169 | | | | | 3 weeks after receiving dietary information , .11
| | Tailored feedback | 178 | | | | | 3 weeks after receiving dietary information, .39 | | p<.01 for diff between tailored and control group
Silk, 2008^32^ | Likeability of learning materials (hypothesis 1) [authors identify 3 subscales -- attention, understanding, intention] | Pamphlet | 57 | Likeability was measured using 9 items on a 5-point Likert-type scale. mean, no measure SD, | | | | 10–12days: mean, 3.99 SD, 0.66 | | p<0.05
Silk, 2008^32^ | Likeability of learning materials (hypothesis 1) [authors identify 3 subscales -- attention, understanding, intention] | Website | 51 | Likeability was measured using 9 items on a 5-point Likert-type scale. | | | | 10–12days: mean, 4.29 SD, 0.45 | | p<0.05
Silk, 2008^32^ | Likeability of learning materials (hypothesis 1) [authors identify 3 subscales -- attention, understanding, intention] | Video game | 47 | Likeability was measured using 9 items on a 5-point Likert-type scale. | | | | 10–12days: mean, 4.06 SD, 0.66 | | p<0.05
Silk, 2008^32^ | Nutrition literacy scores (hypothesis 2) [authors identify 6 subscales: My Pyramid, Food groups, Food servings, Serving size, Food safety, Food cost] | Pamphlet | 57 | Knowledge questions were based on the EFNEP Evaluation and Reporting System developed by USDA for EFNEP at the federal level (33 items) | | | | 10–12days mean, 24.75 SD, 4.76 | | p<.05
Silk, 2008^32^ | Nutrition literacy scores (hypothesis 2) [authors identify 6 subscales: My Pyramid, Food groups, Food servings, Serving size, Food safety, Food cost] | Website | 51 | Knowledge questions were based on the EFNEP Evaluation and Reporting System developed by USDA for EFNEP at the federal level (33 items) | | | | 10–12days mean, 25.59 SD, 3.56 | | p<.05
Silk, 2008^32^ | Nutrition literacy scores (hypothesis 2) [authors identify 6 subscales: My Pyramid, Food groups, Food servings, Serving size, Food safety, Food cost] | Video game | 47 | Knowledge questions were based on the EFNEP Evaluation and Reporting System developed by USDA for EFNEP at the federal level (33 (Items) | | | | 10–12days mean, 23.17 SD, 4.95 | | p<.05
Overweight and binge eating
Jones, 2008^33^ | BMI (kg/m^2^) | Control | 43 | Mean, 30.64 SD, 5.97 | Post Treatment mean, 29.99 SD, 5.92 | | | 16 weeks: mean, 31.17 SD, 6.33
Jones, 2008^33^ | BMI (kg/m^2^) | SB2-BED | 44 | Mean, 30.58 SD, 4.9 | Post Treatment mean, 28.76 SD, 4.72 | | | 16 weeks: mean, 29.76 SD, 5.34 | | p<.001
Jones, 2008^33^ | BMIzScore | Control | 43 | Mean, 1.79 SD, 0.51 | Post Treatment mean, 1.68 SD, 0.54 | | | 16 weeks mean, 1.76 SD, 0.57
Jones, 2008^33^ | BMIzScore | SB2-BED | 44 | Mean, 1.81 SD, 0.47 | Post Treatment mean, 1.56 SD, 0.59 | | | 16 weeks mean, 1.6 SD, 0.62 | | p<.001
Jones, 2008^33^ | Binge eating (OBEs and SBEs) | Control | 43 | No. of episodes mean, 8.42 SD, 18.74 | Post Treatment mean, 6.98 SD, 17.55 | | | 16 weeks mean, 2.74 SD, 8.6
Jones, 2008^33^ | Binge eating (OBEs and SBEs) | SB2-BED | 44 | No. of episodes mean, 15.16 SD, 20.78 | Post Treatment mean, 0.95 SD, 3.88 | | | 16 weeks mean, 2.29 SD, 7.67 | | p<.05
Jones, 2008^33^ | Binge eating (OOEs) | Control | 43 | No. of episodes mean, 7.53 SD, 14.28 | Post Treatment mean, 2.34 SD, 5.25 | | | 16 weeks mean, 1.07 SD, 2.80
Jones, 2008^33^ | Binge eating (OOEs) | SB2-BED | 44 | No. of episodes mean, 7.89 SD, 14.28 | Post Treatment mean, 2.05 SD, 6.98 | | | 16 weeks mean, 2.16 SD, 9.33 | | NS
Jones, 2008^33^ | Weight and shape concerns | Control | 43 | Score mean, 1.35 SD, 0.92 | Post Treatment mean, 1.27 SD, 0.78 | | | 16 weeks mean, 1.14 SD, 0.72
Jones, 2008^33^ | Weight and shape concerns | SB2-BED | 44 | Score: mean, 1.3 SD, 0.80 | Post Treatment mean,1.05 SD, 0.64 | | | 16 weeks mean, 0.81 SD, 0.67 | | p<0.05
Jones, 2008^33^ | Dietary fat intake | Control | 43 | Score: mean, 22.06 SD, 10.73 | Post Treatment: mean, 20.05 SD, 7.49 | | | 16 weeks: mean, 17.33 SD, 7.57
Jones, 2008^33^ | Dietary fat intake | SB2-BED | 44 | Score: mean, 24.54 SD, 8.63 | Post Treatment: mean, 18.88 SD, 6.56 | | | 16 weeks: mean, 18.25 SD, 6.95 | | NS
Jones, 2008^33^ | Depressed mood | Control | 43 | Score: mean, 15.63 SD, 10.33 | Post Treatment mean, 12.57 SD, 10.10 | | | 16 weeks mean, 10.49 SD, 11.21
Jones, 2008^33^ | Depressed mood | SB2-BED | 44 | Score: mean, 14.26 SD, 9.43 | Post Treatment mean, 9.63 SD, 8.30 | | | 16 weeks mean, 12.42 SD, 11.59 | | NS

NS = Not Significant, BL = baseline, SD =Standard Deviation, BMI= Body Mass Index

Reference List

1 Adachi Y, Sato C, Yamatsu K, Ito S, Adachi K, Yamagami T. A randomized controlled trial on the long-term effects of a 1-month behavioral weight control program assisted by computer tailored advice. Behav Res Ther 2007; 45(3):459–70.

2 Anderson ES, Winett RA, Wojcik JR, Winett SG, Bowden T. A computerized social cognitive intervention for nutrition behavior: Direct and mediated effects on fat, fiber, fruits, and vegetables, self-efficacy, and outcome expectations among food shoppers. 2001; 23(2):88–100.

3 Brug J, Glanz K, Van Assema P, Kok G, Van Breukelen GJP. The Impact of Computer-Tailored Feedback and Iterative Feedback on Fat, Fruit, and Vegetable Intake. 1998; 25(4):517–31.

4 Brug J, Steenhuis I, Van Assema P, Glanz K, De Vries H. Computer-tailored nutrition education: Differences between two interventions. 1999; 14(2):249–56.

5 Campbell MK, DeVellis BM, Strecher VJ, Ammerman AS, DeVellis RF, Sandler RS. Improving dietary behavior: The effectiveness of tailored messages in primary care settings. 1994; 84(5):783–7.

6 Campbell MK, Honess-Morreale L, Farrell D, Carbone E, Brasure M. A tailored multimedia nutrition education pilot program for low-income women receiving food assistance. 1999; 14(2):257–67.

7 Campbell MK, Carbone E, Honess-Morreale L, Heisler-MacKinnon J, Demissie S, Farrell D. Randomized trial of a tailored nutrition education CD-ROM program for women receiving food assistance. 2004; 36(2):58–66.

8 Haerens L, De Bourdeaudhuij I, Maes L, Vereecken C, Brug J, Deforche B. The effects of a middle-school healthy eating intervention on adolescents' fat and fruit intake and soft drinks consumption. 2007; 10(5):443–9.

9 Haerens L, Deforche B, Maes L, Brug J, Vandelanotte C, De Bourdeaudhuij I. A computer-tailored dietary fat intake intervention for adolescents: results of a randomized controlled trial. Ann Behav Med 2007; 34(3):253–62.

10 Haerens L, Maes L, Vereecken C, De Henauw S, Moreno L, De Bourdeaudhuij I. Effectiveness of a computer tailored physical activity intervention in adolescents compared to a generic advice. Patient Educ Couns 2009.

11 Hurling R, Fairley BW, Dias MB. Internet-based exercise intervention systems: Are more interactive designs better? 2006; 21(6):757–72.

12 Hurling R, Catt M, Boni MD et al. Using internet and mobile phone technology to deliver an automated physical activity program: randomized controlled trial. J Med Internet Res 2007; 9(2):e7.

13 King DK, Estabrooks PA, Strycker LA, Toobert DJ, Bull SS, Glasgow RE. Outcomes of a multifaceted physical activity regimen as part of a diabetes self-management intervention. 2006; 31(2):128–37.

14 Kristal AR, Curry SJ, Shattuck AL, Feng Z, Li S. A randomized trial of a tailored, self-help dietary intervention: The puget sound eating patterns study. 2000; 31(4):380–9.

15 Lewis B, Williams D, Dunsiger S et al. User attitudes towards physical activity websites in a randomized controlled trial. Prev Med 2008; 47(5):508–13.

16 Low KG, Charanasomboon S, Lesser J et al. Effectiveness of a computer-based interactive eating disorders prevention program at long-term follow-up. Eat Disord 2006; 14(1):17–30.

17 Mangunkusumo R, Brug J, Duisterhout J, de Koning H, Raat H. Feasibility, acceptability, and quality of Internet-administered adolescent health promotion in a preventive-care setting. Health Educ Res 2007; 22(1):1–13.

18 Marcus BH, Lewis BA, Williams DM et al. A comparison of Internet and print-based physical activity interventions. Arch Intern Med 2007; 167(9):944–9.

19 Napolitano MA, Fotheringham M, Tate D et al. Evaluation of an internet-based physical activity intervention: a preliminary investigation. Ann Behav Med 2003; 25(2):92–9.

20 Oenema A, Brug J, Lechner L. Web-based tailored nutrition education: results of a randomized controlled trial. Health Educ Res 2001; 16(6):647–60.

21 Oenema A, Tan F, Brug J. Short-term efficacy of a web-based computer-tailored nutrition intervention: main effects and mediators. Ann Behav Med 2005; 29(1):54–63.

22 Richardson CR, Mehari KS, McIntyre LG et al. A randomized trial comparing structured and lifestyle goals in an internet-mediated walking program for people with type 2 diabetes. Int J Behav Nutr Phys Act 2007; 4:59.

23 Smeets T, Kremers SP, Brug J, de Vries H. Effects of tailored feedback on multiple health behaviors. Ann Behav Med 2007; 33(2):117–23.

24 Spittaels H, De Bourdeaudhuij I, Vandelanotte C. Evaluation of a website-delivered computer-tailored intervention for increasing physical activity in the general population. 2007; 44(3):209–17.

25 Spittaels H, De Bourdeaudhuij I, Brug J, Vandelanotte C. Effectiveness of an online computer-tailored physical activity intervention in a real-life setting. Health Educ Res 2007; 22(3):385–96.

26 Tate DF, Jackvony EH, Wing RR. A randomized trial comparing human e-mail counseling, computer-automated tailored counseling, and no counseling in an Internet weight loss program. Arch Intern Med 2006; 166(15):1620–5.

27 Vandelanotte C, De Bourdeaudhuij I, Sallis JF, Spittaels H, Brug J. Efficacy of sequential or simultaneous interactive computer-tailored interventions for increasing physical activity and decreasing fat intake. Ann Behav Med 2005; 29(2):138–46.

28 Verheijden M, Bakx JC, Akkermans R et al. Web-based targeted nutrition counselling and social support for patients at increased cardiovascular risk in general practice: randomized controlled trial. J Med Internet Res 2004; 6(4):e44.

29 Wylie-Rosett J, Swencionis C, Ginsberg M et al. Computerized weight loss intervention optimizes staff time: The clinical and cost results of a controlled clinical trial conducted in a managed care setting. 2001; 101(10):1155–62.

30 Winzelberg AJ, Eppstein D, Eldredge KL et al. Effectiveness of an Internet-based program for reducing risk factors for eating disorders. J Consult Clin Psychol 2000; 68(2):346–50.

31 Brug J, Steenhuis I, Van Assema P, De Vries H. The impact of a computer-tailored nutrition intervention. 1996; 25(3):236–42.

32 Silk KJ, Sherry J, Winn B, Keesecker N, Horodynski MA, Sayir A. Increasing nutrition literacy: testing the effectiveness of print, web site, and game modalities. J Nutr Educ Behav 2008; 40(1):3–10.

33 Jones M, Luce KH, Osborne MI et al. Randomized, controlled trial of an internet-facilitated intervention for reducing binge eating and overweight in adolescents. Pediatrics 2008; 121(3):453–62.

Evidence table 11

Description of RCTs addressing the impact of CHI applications on intermediate outcomes in alcohol abuse (KQ1b)

Author, year | Consumer under study | CHI Application type | Location | Year data collected/duration of intervention | Inclusion criteria | Exclusion criteria | Control | Intervention | Jadad score
Alcohol Abuse
Cunningham, 2005^1^ | Individuals interested in their own health care | Interactive consumer website, | Home/residence | 2 yr | | | After intervention, did not receive additional self-help information by postal mail | After intervention, received additional self-help materials by postal mail | 1.5
Hester, 2005^2^ | Individuals interested in their own health care | Personalized health risk assessment tool | Home/residence | NS | ≤21 yr old, Minimum score of 8 on Alcohol Use Disorders Inventory Test, At least 8th grade reading level, Available and willing significant other to corroborate self-report of drinking | Current alcohol treatment, Severe uncontrolled thought disorder, Presence of a medical condition for which alcohol use would be contraindicated | Delayed treatment | | 2
Kypri, 1999^3^ | Individuals interested in their own health care | Personalized health risk assessment tool | Home/residence | 2002/NS | 17–26 yr old, Score of 8 or more on the Alcohol Use Disorders Identification Test, Consuming more than 4/6 standard drinks (F/M) on one more occasions in the preceding 4 weeks | | Leaflet on health effects of alcohol | Web-based assessment and personalized feedback on their drinking | 4
Lieberman, 2006^4^ | Individuals interested in their own health care | Interactive consumer website | NS | 18 months | | | Text website | Multimedia website | −0.5
Neighbors, 2004^5^ | Individuals interested in their own health care | Interactive consumer website | Remote location: “Controlled setting on campus” | NS | At least one heavy drinking episode at one sitting in the previous month | | No intervention | Personalized normative feedback | 1
Riper, 2008^6^ | Adult alcohol drinkers | Web-based self help intervention | Data from other RCT | NS | Men who were drinking more than 21 standard units per week, women who were drinking over 14 units per week, age 18–65, access to the internet, no previous professional help for problem drinking | Insufficient alcohol use, above age 65, alcohol-related medication, professional help, in other alcohol study; incomplete data, non-response, in same household | Control condition (an online psycho educational brochure on alcohol use that could be read in 10 minutes) | The experimental condition participants access to web-based self help intervention without therapist
Riper, 2008^7^ | Individuals interested in their own health care | Interactive consumer website | NS | Yr 2003 | 18–65 yr, Men were selected who were drinking either more than 21 units per week (excessive drinking) or 6 or more units at least 1 day per week for the past 3 months (hazardous drinking). Women were included if they drank over 14 units a week or 4 or more units at least 1 day a week for the past 3months. Access to the internet. Not receiving professional help for problem drinking at the start of the study. | | Control condition | Experimental condition | 2

Yr = year, NS= Not Specified

Reference List

1 Cunningham JA, Humphreys K, Koski-Jannes A, Cordingley J. Internet and paper self-help materials for problem drinking: is there an additive effect? Addict Behav 2005; 30(8):1517–23.

2 Hester RK, Squires DD, Delaney HD. The Drinker’s Check-up: 12-month outcomes of a controlled clinical trial of a stand-alone software program for problem drinkers. J Subst Abuse Treat 2005; 28(2):159–69.

3 Kypri K, Saunders JB, Williams SM et al. Web-based screening and brief intervention for hazardous drinking: a double-blind randomized controlled trial. Addiction 2004; 99(11):1410–7.

4 Lieberman DZ. Effects of a personified guide on adherence to an online program for alcohol abusers. Cyberpsychol Behav 2006; 9(5):603–7.

5 Neighbors C, Larimer ME, Lewis MA. Targeting misperceptions of descriptive drinking norms: efficacy of a computer-delivered personalized normative feedback intervention. J Consult Clin Psychol 2004; 72(3):434–47.

6 Riper H, Kramer J, Keuken M, Smit F, Schippers G, Cuijpers P. Predicting successful treatment outcome of web-based self-help for problem drinkers: secondary analysis from a randomized controlled trial. J Med Internet Res 2008; 10(4):e46.

7 Riper H, Kramer J, Smit F, Conijn B, Schippers G, Cuijpers P. Web-based self-help for problem drinkers: a pragmatic randomized trial. Addiction 2008; 103(2):218–27.

Evidence Table 12

Description of consumer characteristics in addressing impact of CHI applications on intermediate outcomes in alcohol abuse

Author, year | Control Interventions | Age | Race, n (%) | Income | Education, n (%) | SES | Gender, n (%) | Marital Status | Other characteristics
alcohol abuse
Cunningham, 2005^1^ | After intervention, did not receive additional self-help information by postal mail | Baseline characteristics not reported
Cunningham, 2005^1^ | Internet plus book | Baseline characteristics not reported
Hester, 2005^2^ | Delayed treatment | Baseline characteristics not reported
Hester, 2005^2^ | DCU/ Immediate treatment group | Baseline characteristics not reported
Kypri, 1999^3^ | Leaflet on health effects of alcohol | Mean, 20.4 SD, 1.8 | NS | NS | NS | NR | | | AUDIT score, mean, 16.6 SD, 6
Kypri, 1999^3^ | Web-based assessment and personalized feedback on their drinking | Mean, 19.9 SD, 1.4 | NS | NS | NS | NR | | | AUDIT score, mean, 16.6 SD, 6
Lieberman, 2006^4^ | Text website | Mean, 37.2 SD, 11.8 | White non Hispanic, (87) Black non-Hispanic, (1.7) Latino/Hispanic, (7) API, (2.3) AIAN , (2.3) Other, 6.5 | NS | NS | NR | F, (37.2) | | Age of first drink, mean, 16.4 SD, 3.9 Drinks per week, mean, 34.3 SD, 31.6 AUDIT score, mean, 17 SD, 8.8
Lieberman, 2006^4^ | Multimedia website | Mean, 36 SD, 12.1 | White non-Hispanic, (86.8) Black non-Hispanic, (1.6) Latino/Hispanic, (4.1) API, (4.1) AIAN, (2.5) No response, (5.0 ) | NS | NS | NR | F, (31) | | Age of first drink, mean, 17.4 SD, 5.5 Drinks per week, mean, 32.4 SD, 50.8 AUDIT score, mean, 15.7 SD, 8.4
Neighbors, 2004^5^ | No intervention | NS | NS | NS | NS | NR | M, 54 F, 72
Neighbors, 2004^5^ | Intervention (personalized normative feedback) | NS | NS | NS | NS | NR | M, 50 F, 76
Riper, 2008^6^ | Control: alcohol information brochure | Control: mean 46.2 SD,9.2 | NS | Paid employment control: 96 (73.3) | Control low 38 (29.0) High 93 (71.0) | NS | F 64(48.9) | | High Internet competence100 (76.3) High treatment expectancy 66 (49.6) Weekly alcohol intake 43.5 (22.3) Moderate problem drinking74 (56.5) Sever problem drinking 57 (43.5) Prior professional help for problem drinking 15 (11.5) Contemplation stage 115 (87.8) Alcohol moderation as goal 123 (93.9) Living with a partner 71 (54.2)
Riper, 2008^6^ | Intervention: drinking less (free-access, Web-based self-help intervention without therapist guidance. | Experimental : mean 45.9 SD,8.9 | NS | Paid employment control: 96 (73.3) | Low 41 (31.5) High 89 (68.5) | NS | F 64(49.2) | | High Internet competence 104 (80.0) High treatment expectancy 61 (46.9) Weekly alcohol intake 43.7 (21.0) Moderate problem drinking 74 (56.9) Sever problem drinking 56 (43.1) Prior professional help for problem drinking18 (13.8) Contemplation stage 116 (89.2) Alcohol moderation as goal 120 (92.3) Living with a partner 71 (54.2) 75 (57.7)
Riper, 2008^7^ | Control condition (PBA) | Mean, 46.2 SD, 9.2 | NS | NS | Unskilled, 38 (29.0) Vocational, 55 (42.0) Academic, 38 (29.0) | NR | F, 64 (48.9) | | Problem drinking, 131 (100) Excessive drinking, 128 (97.7)
Riper, 2008^7^ | Experimental condition (DL) | Mean, 45.9 SD, 8.9 | NS | NS | Unskilled, 41 (31.5) Vocational, 52 (40.0) Academic, 37 (28.5) | NR | F, 64 (49.2) | | Problem drinking, 130 (100) Excessive drinking, 125 (96.2)

NR= Not Reported, NS= Not specified, SD= Standard Deviation, SES= Socioeconomic Status, AIAN= American Indian/Alaska Native, API = Asian/Pacific Islander

F = female, M = Male

Reference List

1 Cunningham JA, Humphreys K, Koski-Jannes A, Cordingley J. Internet and paper self-help materials for problem drinking: is there an additive effect? Addict Behav 2005; 30(8):1517-23.

2 Hester RK, Squires DD, Delaney HD. The Drinker's Check-up: 12-month outcomes of a controlled clinical trial of a stand-alone software program for problem drinkers. J Subst Abuse Treat 2005; 28(2):159-69.

3 Kypri K, Saunders JB, Williams SM et al. Web-based screening and brief intervention for hazardous drinking: a double-blind randomized controlled trial. Addiction 2004; 99(11):1410-7.

4 Lieberman DZ. Effects of a personified guide on adherence to an online program for alcohol abusers. Cyberpsychol Behav 2006; 9(5):603-7.

5 Neighbors C, Larimer ME, Lewis MA. Targeting misperceptions of descriptive drinking norms: efficacy of a computer-delivered personalized normative feedback intervention. J Consult Clin Psychol 2004; 72(3):434-47.

6 Riper H, Kramer J, Keuken M, Smit F, Schippers G, Cuijpers P. Predicting successful treatment outcome of web-based self-help for problem drinkers: secondary analysis from a randomized controlled trial. J Med Internet Res 2008; 10(4):e46.

7 Riper H, Kramer J, Smit F, Conijn B, Schippers G, Cuijpers P. Web-based self-help for problem drinkers: a pragmatic randomized trial. Addiction 2008; 103(2):218-27.

Evidence table 13

All outcomes in studies addressing the impact of CHI applications on intermediate outcomes in alcohol abuse (KQ1b)

Author, year | Outcomes | Control Intervention | n | Measure at BL | Measure at time point 2 | Measure at time point 3 | Measure at final time point | Ratios at time points | Significance
Alcohol Abuse
Cunningham, 2005^1^ | Mean drinks per typical week | Internet alone | 29 | Mean, 21 SD, 16.6 | | | 3 months mean, 17.4 SD, 17.7
Cunningham, 2005^1^ | Mean drinks per typical week | Internet plus self help book | 19 | Mean, 29.1 SD, 23.2 | | | 3 months mean, 18.4 SD, 25.8 | | p<0.05
Cunningham, 2005^1^ | Mean AUDIT test score | Internet alone | 29 | Mean, 15.6 SD, 8.9 | | | 3 months mean, 12.6 SD, 7.8
Cunningham, 2005^1^ | Mean AUDIT test score | Internet plus book | 19 | Mean, 19.8 SD, 10.3 | | | 3 months mean, 11.9 SD, 9.9 | | p<0.05
Cunningham, 2005^1^ | Mean # of alcohol consequences | Internet alone | 29 | Mean, 2.4 SD, 1.9 | | | 3 months Mean, 1.9 SD, 1.6
Cunningham, 2005^1^ | Mean # of alcohol consequences | Internet plus book | 19 | Mean, 2.9 SD, 1.8 | | | 3 months mean, 1.5 SD, 1.6 | | p<0.05
Hester, 2005^2^ | Average drinks per day | DCU/4 week Delayed treatment group | 21 | Mean, 5.64 SD, 4.66 | 4 weeks mean, 4.13 SD, 2.61 | 8 weeks mean, 3.56 SD, 2.8 | 12 months median, 2.5 SD, 2.58 | | P 0.008
Hester, 2005^2^ | Average drinks per day | DCU/ Immediate treatment group | 29 | Mean, 5.69 SD, 5.44 | 4 weeks mean, 2.71 SD, 2.84 | 8 weeks mean, 2.31 SD, 2.23 | 12 months mean, 2.07 SD, 2.19 | | P 0.002
Hester, 2005^2^ | Drinks per drinking day | DCU/4 week Delayed treatment group | 21 | Mean, 5.57 SD, 2.55 | 4 weeks mean, 5.66 SD, 2.6 | 8 weeks mean, 4.86 SD, 2.4 | 12 months mean, 4.14 SD, 2.72 | | NR
Hester, 2005^2^ | Drinks per drinking day | DCU/Immediate treatment group | 29 | Mean, 8.84 SD, 6.36 | 4 weeks mean, 5.64 SD, 4.09 | 8 weeks mean, 6.66 SD, 6.12 | 12 months mean, 5.5 SD, 4.63 | | NR
Hester, 2005^2^ | Average peak BAC | DCU/4 week Delayed treatment group | 21 | Mean, 0.161 SD, 0.132 | 4 weeks mean, 0.149 SD, 0.106 | 8 weeks mean, 0.1 SD, 0.079 | 12 months mean, 0.073 SD, 0.063 | | P 0.003
Hester, 2005^2^ | Average peak BAC | DCU/ Immediate treatment group | 29 | Mean, 0.174 SD, 0.107 | 4 weeks mean, 0.096 SD, 0.087 | 8 weeks mean, 0.118 SD, 0.126 | 12 months mean, 0.078 SD, 0.058 | | P 0.001
Kypri , 1999^3^ | Drinking frequency | Control | 47 | N of drinking days in last 2 weeks | 6 weeks median, 4 range, 0–13 | | 6 months: median, 4 range, 0–14
Kypri , 1999^3^ | Drinking frequency | Computerized assessment and behavioral intervention | 47 | N of drinking days in last 2 weeks | 6 weeks median, 3 range, 0–9 | | 6 months median, 3 range, 0–8 | | NR
Lieberman, 2006^4^ | Number of modules completed | Control | NS | Number of modules (1–4) | | | After completing each of 4 modules mean, 3.69
Lieberman, 2006^4^ | Number of modules completed | Multimedia | NS | | | | After completing each of 4 modules mean, 3.9 | | 0.01
Lieberman, 2006^4^ | Perceived helpfulness of the modules | Control | | Helpfulness scores (rating the 4 modules) | | | After completing each of 4 modules mean, 12.1
Lieberman, 2006^4^ | Perceived helpfulness of the modules | Multimedia | | Helpfulness scores (rating the 4 modules) | | | After completing each of 4 modules mean, 12.2 | | 0.74
Neighbors , 2004^5^ | Effect size in perceived norms | Control | 126 | Effect Size | 3 months mean, .17 | | 6 months mean, .2
Neighbors , 2004^5^ | Effect size in perceived norms | Computerized normative feedback | 126 | Effect size | 3 months mean, .46 | | 6 months mean, .48 | | NR
Neighbors , 2004^5^ | Effect size in reduction in alcohol consumption | Control | 126 | Effect Size | 3 months mean, .05 | | 6 months mean, .03
Neighbors , 2004^5^ | Effect size in reduction in alcohol consumption | Computerized normative feedback | 126 | Effect Size | 3 months mean, .24 | | 6 months mean, .22 | | p<0.01
Neighbors , 2004^5^ | Effect size in reduction in alcohol consumption | Control | 126 | Effect Size | 3 months | | 6 months
Neighbors , 2004^5^ | Effect size in reduction in alcohol consumption | Computerized normative feedback | 126 | Effect Size | 3 months | | 6 months
Riper, 2008^6^ | Mean alcohol consumption difference between baseline and 6 months and 12 month follow up period. | Control: alcohol information brochure | 131 | Follow up at 6 month n 81 (61.8) | | | Follow up at 12 month n 92(70.2) | NS
Riper, 2008^6^ | Mean alcohol consumption difference between baseline and 6 months and 12 month follow up period. | Control: alcohol information brochure | 131 | Loss to follow-up at 6 month n 50 (38.2) | | | Loss to follow up at 12 month n 39(29.8) | NS
Riper, 2008^6^ | Mean alcohol consumption difference between baseline and 6 months and 12 month follow up period. | Intervention: drinking less(free-access, Web-based self-help intervention without therapist guidance. | 130 | Follow up at 6 month n 70 (53.8) | | | Follow up at 12 month n 71(54.6) | NS | Females displayed modest predictive power at 6 month P .05 at 12 month P .045 With higher levels of education modest predictive power P .01
Riper, 2008^6^ | Mean alcohol consumption difference between baseline and 6 months and 12 month follow up period. | Intervention: drinking less(free-access, Web-based self-help intervention without therapist guidance. | 130 | Loss to follow-up at 6 month n 60 (46.2) | | | Loss to follow up at 12 month n 59(45.4) | NS | Females displayed modest predictive power at 6 month P .05 at 12 month P .045 With higher levels of education modest predictive power P .01
Riper, 2008^7^ | Weekly alcohol consumption (second outcomes) | Control | 81 | Weekly alcohol intake in std units mean, 43.5 SD, 22.3 | | | 6months mean, 39.2 | Difference in means, 10.6 (95) (CI, 4.33–16.94) | P 0.001
Riper, 2008^7^ | Weekly alcohol consumption (second outcomes) | Intervention condition DL | 70 | Weekly alcohol intake in std units mean, 43.7 SD, 21 | | | 6months mean, 28.7

SD = Standard deviation, BL = baseline, CI = confidence interval, DCU = Drinker’s Check-up, NR = Not reported

Reference List

1 Cunningham JA, Humphreys K, Koski-Jannes A, Cordingley J. Internet and paper self-help materials for problem drinking: is there an additive effect? Addict Behav 2005; 30(8):1517–23.

2 Hester RK, Squires DD, Delaney HD. The Drinker's Check-up: 12-month outcomes of a controlled clinical trial of a stand-alone software program for problem drinkers. J Subst Abuse Treat 2005; 28(2):159–69.

3 Kypri K, Saunders JB, Williams SM et al. Web-based screening and brief intervention for hazardous drinking: a double-blind randomized controlled trial. Addiction 2004; 99(11):1410–7.

4 Lieberman DZ. Effects of a personified guide on adherence to an online program for alcohol abusers. Cyberpsychol Behav 2006; 9(5):603–7.

5 Neighbors C, Larimer ME, Lewis MA. Targeting misperceptions of descriptive drinking norms: efficacy of a computer-delivered personalized normative feedback intervention. J Consult Clin Psychol 2004; 72(3):434–47.

6 Riper H, Kramer J, Keuken M, Smit F, Schippers G, Cuijpers P. Predicting successful treatment outcome of web-based self-help for problem drinkers: secondary analysis from a randomized controlled trial. J Med Internet Res 2008; 10(4):e46.

7 Riper H, Kramer J, Smit F, Conijn B, Schippers G, Cuijpers P. Web-based self-help for problem drinkers: a pragmatic randomized trial. Addiction 2008; 103(2):218–27.

Evidence Table 14

Description of RCTs addressing impact of CHI applications on intermediate outcomes in smoking (KQ1b)

Author, year | Consumer under study | CHI Application type | Location | Year data collected/duration of intervention | Inclusion criteria | Exclusion criteria | Control | Intervention | Jadad score
Smoking
An, 2008^1^ | Individuals interested in their own health care | Interactive consumer website | University of Minnesota internet health screening | 2004 | ≥18 yr, Smoked cigarettes in the past 30 days, indicated that they intended to be in school for the next two semesters | | Control group | RealU intervention group | 2
Brendryen, 2008^2^ | Smokers in Norway | Internet and cell phone | Online | 2006/February 2006 to March, 2007 | 18 years or older, Willing to quit on March 6, 2006, currently smoking five cigarettes or more a day, willing to quit without using NRT, owning a mobile phone, owning a Norwegian-registered phone number and postal address, and having daily access to the Internet and email. | NR | Self-help booklet | Happy Ending program (HE)
Curry, 1995^3^ | Random sample of group health cooperative enrollees | Computer generated tailored feedback | Residence | NS/21 months | Self-identified smoker | | No treatment | Booklet (self-help booklet) Feedback (self-help booklet + personalized feedback) Phone (Booklet + Feedback + Counselor phone call)
Dijkstra, 2005^4^ | Students who are smokers | Information | Laboratory at university | NR/One session | Student who is a smoker | NR | Standard information | Personalization Adaptation Feedback
Hang, 2009^5^ | Daily smoker | SMS messaging | University | 2007/August to December | Daily smoker, use SMS (text messaging) at least weekly | NR | No intervention | 1 SMS per week 3 SMS per week
Japuntich, 2006^6^ | Individuals interested in their own health care | Interactive consumer website | Home/residence | Recruitment took place from October 2001 to July 2002. | ≥18 yr, Smoke at least 10 cigarettes per day, Have a traditional telephone line, Literate in English | Current depression, current use of psychiatric medication, medical conditions contraindicating bupropion SR (e.g., history of seizure disorder), current use of a smoking cessation product or treatment, Being pregnant or likely to become pregnant during the treatment phase of the study | bupropion plus counseling alone | CHESS intervention with bupropion | 2
Pattens, 2006^7^ | Individuals interested in their own health care, adolescent smokers | Interactive consumer website | Clinician office | March 2000 to November 2003 | 11–18 yr, gave written consent or received consent from parent/guardian, 18 yr, Smoked 10 or more cigarettes in last 30 days, Cigarettes were primary tobacco product used, Willing and able to complete treatment assessment visits | Homeless, Alcohol or drug abuse in the last 3 months | Brief office intervention | Stomp Out Smokes | 1
Prochaska, 1993^8^ | Volunteer smokers in Rhode Island | Tailored manuals and computer reports | Residence | NS/18 months | Smokers who responded to advertisement | | ALA + (standard self-help manual) | TTT (individualized manual) ITT (interactive computer reports) PITT (personalized counselor calls + ITT TTT)
Prokhorov, 2008^9^ | Students in culturally diverse high schools | Interactive CD-ROM | High school | NS/4 years | 10^th^ grade Speaks, reads and writes English | | Clearing the Air self-help booklet | ASPIRE Interactive CD-ROM
Schiffman, 2000^10^ | Individuals interested in their own health care | Computer tailored mailings via computer assisted automated telephone interviews | Home/residence | 1996/NS | ≥18 yr, Current cigarette smoker, Purchased 2 or 4 mg nicotine prolacrilex gum, Were attempting to quit smoking cigarettes, Target quit date was within 7 days of enrollment, Agreed to be contacted at follow up at 6 and 12 weeks | | User Guide only | Committed Quitter Program | 2.5
Schumann, 2006^11^ | Smokers drawn from representative population of 20–79 year olds living in Western Pomeania, GERMANY | Computer generated tailored feedback | Residence | 2002 – 2004/24 months | Provided written informed consent and said yes to a question about currently smoking | | No intervention | Feedback letters
Schumann, 2008^12^ | Individuals interested in their own health care | Letters entered into a system with PHI and generating tailored information for the consumer | NS | Started in April 2002 | 20–79 yr, Currently smoke cigarettes, Currently smoke cigars or cigarillos, Currently a pipe smoker | | Assessment-only control group | Computer-tailored TTM-based intervention group | 2.5
Severson, 2008^13^ | Individuals interested in their own health care | Interactive consumer website | Online | NS | At least 18 yr old, Male, A resident of the US or Canada, E-mail address checked at least weekly, any ST user (defined as having used ST for at least 1 year and used at least at in a week), and willing to provide his or her name, mailing address, and phone number | | Text-based website (Basic Condition) | Tailored web-based intervention (Enhanced Condition) | 2
Strecher, 1994^14^ Study 1 | Adult cigarette smokers in North Carolina | Computer generated tailored feedback | Residence | Study 1: 1990/4 months | 40–65 years old, seen by family physician in last 6 months, telephone available and working, not sharing household with other subject, mentally and physically capable of being interviewed. | | Standardized generic letter | Tailored letter from individual’s physician
Strecher, 2005^15^ | Callers to NCI CIS call centers | | | | 18 yrs or older, English as a primary language, smoked at least five cigarettes per day, interested in quitting, not currently in another cessation program, not currently undergoing or planning cancer treatment
Strecher, 2005^16^ | Individuals interested in their own health care | Interactive consumer website | NS | | ≥18 yr, Target quit date within 7 days, Valid email address, Internet access, Smoke more than 10 cig/day Purchased NiQuitin CQ 21 mg, Agreed to contact for FU email and questionnaire at 6 and 12 weeks | | | | −1
Strecher, 2006^17^ | Individuals interested in their own health care | Interactive consumer website | Home/residence | NS | ≥ 18 yr, Smokers in the United Kingdom and Republic of Ireland who purchased NiQuitin CQ 21-mg patch and connected to a Web site to enroll for free behavioral support materials, Had a target quit date that was within seven days from the enrollment date, Provided a valid e-mail address and had Internet access for the duration of the study, Were attempting to quit smoking cigarettes (i.e., not smokeless tobacco), Had been smoking more than 10 cigarettes per day, had purchased NiQuitin CQ 21 mg (21 mg of nicotine; indicated for those who smoke at least 10 cigarettes per day), Agreed to be contacted for follow-up e-mail and Web-based questionnaires at 6 and 12 weeks | | Non-tailored Web-based cessation material | Tailored web-based smoking cessation (CQ PLAN) | 0.5
Strecher, 2008^18^ | Individuals interested in their own health care | Interactive consumer website | NS | September 2004 | 21–70 yr, had smoked at least 100 cigarettes in his or her lifetime, Currently smoked at least 10 cigarettes/day, and had smoked in the past 7 days, was seriously considering quitting in the next 30 days, was a member of either Group Health or HFHS, had home or work access to the Internet and an e-mail account that he or she used at least twice weekly, was not currently enrolled in another formal smoking-cessation program or was not currently using pharmacotherapy for smoking cessation, had no medical contraindications for NRT | Medical contraindications for NRT, Not currently enrolled in the HMO, Lack of adequate Internet/e-mail access, Already enrolled in another smoking-cessation program, Medical contraindications for NRT, Currently using pharmacotherapy to quit smoking | Low-tailored | High-tailored | 0
Swartz, 2006^19^ | Individuals interested in their own health care | Interactive consumer website | Home/residence Remote: work site | NS | >18 yr, Daily smoker, Wish to quit in the next 30 days, Ability to access website | <18 yr | 90 day wait period for access to website | Access to website | 1

NS = not specified, yr = year, NRT = nicotine replacement therapy, CHESS = Comprehensive Health Enhancement Support System

Reference List

1 An LC, Klatt C, Perry CL et al. The RealU online cessation intervention for college smokers: a randomized controlled trial. Prev Med 2008; 47(2):194–9.

2 Brendryen H, Drozd F, Kraft P. A digital smoking cessation program delivered through internet and cell phone without nicotine replacement (happy ending): randomized controlled trial. J Med Internet Res 2008; 10(5):e51.

3 Curry SJ, McBride C, Grothaus LC, Louie D, Wagner EH. A randomized trial of self-help materials, personalized feedback, and telephone counseling with nonvolunteer smokers. 1995; 63(6):1005–14.

4 Dijkstra A. Working mechanisms of computer-tailored health education: Evidence from smoking cessation. 2005; 20(5):527–39.

5 Haug S, Meyer C, Schorr G, Bauer S, John U. Continuous individual support of smoking cessation using text messaging: A pilot experimental study. Nicotine Tob Res 2009.

6 Japuntich SJ, Zehner ME, Smith SS et al. Smoking cessation via the internet: a randomized clinical trial of an internet intervention as adjuvant treatment in a smoking cessation intervention. Nicotine Tob Res 2006; 8 Suppl 1:S59–67.

7 Patten CA, Croghan IT, Meis TM et al. Randomized clinical trial of an Internet-based versus brief office intervention for adolescent smoking cessation. Patient Educ Couns 2006; 64(1–3):249–58.

8 Prochaska JO, DiClemente CC, Velicer WF, Rossi JS. Standardized, Individualized, Interactive, and Personalized Self-Help Programs for Smoking Cessation. 1993; 12(5):399–405.

9 Prokhorov AV, Kelder SH, Shegog R et al. Impact of A Smoking Prevention Interactive Experience (ASPIRE), an interactive, multimedia smoking prevention and cessation curriculum for culturally diverse high-school students. Nicotine Tob Res 2008; 10(9):1477–85.

10 Shiffman S, Paty JA, Rohay JM, Di Marino ME, Gitchell J. The efficacy of computer-tailored smoking cessation material as a supplement to nicotine polacrilex gum therapy. Arch Intern Med 2000; 160(11):1675–81.

11 Schumann A, John U, Rumpf H-J, Hapke U, Meyer C. Changes in the “stages of change” as outcome measures of a smoking cessation intervention: A randomized controlled trial. 2006; 43(2):101–6.

12 Schumann A, John U, Baumeister SE, Ulbricht S, Rumpf HJ, Meyer C. Computer-tailored smoking cessation intervention in a general population setting in Germany: outcome of a randomized controlled trial. Nicotine Tob Res 2008; 10(2):371–9.

13 Severson HH, Gordon JS, Danaher BG, Akers L. ChewFree.com: evaluation of a Web-based cessation program for smokeless tobacco users. Nicotine Tob Res 2008; 10(2):381–91.

14 Strecher VJ, Kreuter M, Den Boer D-J, Kobrin S, Hospers HJ, Skinner CS. The effects of computer-tailored smoking cessation messages in family practice settings. 1994; 39(3):262–70.

15 Strecher VJ, Marcus A, Bishop K et al. A randomized controlled trial of multiple tailored messages for smoking cessation among callers to the cancer information service. J Health Commun 2005; 10 Suppl 1:105–18.

16 Strecher VJ, Shiffman S, West R. Randomized controlled trial of a web-based computer-tailored smoking cessation program as a supplement to nicotine patch therapy. Addiction 2005; 100(5):682–8.

17 Strecher VJ, Shiffman S, West R. Moderators and mediators of a web-based computer-tailored smoking cessation program among nicotine patch users. Nicotine Tob Res 2006; 8 Suppl 1:S95–101.

18 Strecher VJ, McClure JB, Alexander GL et al. Web-based smoking-cessation programs: results of a randomized trial. Am J Prev Med 2008; 34(5):373–81.

19 Swartz LH, Noell JW, Schroeder SW, Ary DV. A randomised control study of a fully automated internet based smoking cessation programme. Tob Control 2006; 15(1):7–12.

Evidence Table 15

Description of consumer characteristics in addressing impact of CHI applications on intermediate outcomes in smoking

Author, year | Control Interventions | Age | Race, n(%) | Income | Education, n(%) | SES | Gender, n(%) | Marital Status | Other characteristics
Smoking
An, 2008^1^ | Control group | Mean, 19.8 SD, 1.6 | Black non-Hispanic, 24(9.2) | NS | Yr in school: Freshman, 80 (30.8) Sophomore, 64 (24.6) Junior, 67 (25.8) Senior, 49(18.9) | NR | F,196 (75.4) | | Employment: Not working, 84 (32.3) Part-time, 159 (61.2) Full-time, 17 (6.5) Internet use: 1–5 days/week, 26 (10.0) 6–7 days/week, 233 (90.0)
An, 2008^1^ | RealU intervention group | Mean, 20.1 SD, 1.6 | Black non-Hispanic, 20(7.8) | NS | Yr in school: Freshman,67 (26.1) Sophomore, 63 (24.5) Junior, 68 (26.5) Senior, 59 (23.0) | NR | F,181 (70.4) | | Employment: Not working, 81 (31.6) Part-time, 161 (62.9) Full-time, 14 (5.5) Internet use: 1–5 days/week, 32 (12.5) 6–7 days/week, 225 (87.6)
Brendryen, 2008^2^ | Self-help booklet | Mean, 39.5 SD, 11.0 | | | Has college degree, 70(49) | | F, 72(50) | | Cigarettes smoked per day Mean 16.6 SD 7.2 Self-efficacy Mean 5.1 SD 1.4
Brendryen, 2008^2^ | Happy Ending program (HE) | Mean, 39.7 SD, 10.8 | | | Has college degree, 76(52) | | F, 73(50) | | Cigarettes smoked per day Mean 17.6 SD 7.0 Self-efficacy Mean 5.1 SD 1.3
Curry, 1995^3^ | Control | Mean, 41.2 SD, 11.9 | White, 285(87) | > $25,000, 230(70) | Finished high school, 302(92) | | F, 157(48) | | No. cigarettes / day Mean, 17.1, SD 10.3 Stage of readiness to quit smoking Precontemplation, 121(37) Contemplation, 134(41) Preparation, 72(22)
Curry, 1995^3^ | Booklet | Mean, 41.3 SD, 11.5 | White, 294(89) | > $25,000, 251(76) | Finished high school, 300(91) | | F, 175(53) | | No. cigarettes / day Mean, 17.2, SD 10.5 Stage of readiness to quit smoking Precontemplation, 125(38) Contemplation, 132(40) Preparation, 69(21)
Curry, 1995^3^ | Feedback | Mean, 40.9 SD, 11.1 | White, 283(86) | > $25,000, 240(73) | Finished high school, 303(92) | | F, 174(53) | | No. cigarettes / day Mean, 17.7, SD 11.1 Stage of readiness to quit smoking Precontemplation, 132(40) Contemplation, 135(41) Preparation, 63(19)
Curry, 1995^3^ | Phone | Mean, 40.8 SD, 11.9 | White, 129(86) | > $25,000, 112(75) | Finished high school, 134(89) | | F, 88(59) | | No. cigarettes / day Mean, 17.1, SD 10.1 Stage of readiness to quit smoking Precontemplation, 65(43) Contemplation, 65(43) Preparation, 22(15)
Dijkstra, 2005^4^ | Standard information | NR | NR | NR | NR | NR | NR | | NR
Dijkstra, 2005^4^ | Personalization
Dijkstra, 2005^4^ | Adaptation
Dijkstra, 2005^4^ | Feedback
Hang, 2009^5^ | No Intervention | Mean, 25.4 SD, 4.9 | NR | NR | > 10 years, 63(98) | NR | F, 40(63) | | Living in a stable partnership, 37(58) Self-efficacy (1–5) Mean 2.7 SD 0.7
Hang, 2009^5^ | 1 SMS per week | Mean, 25.2 SD, 4.8 | | | > 10 years, 46(92) | | F, 28(56) | | Living in a stable partnership, 26(52) Self-efficacy (1–5) Mean 2.7 SD 0.6
Hang, 2009^5^ | 3 SMS per week | Mean, 24.3 SD, 3.8 | | | > 10 years, 54(90) | | F, 31(52) | | Living in a stable partnership, 25(42) Self-efficacy (1–5) Mean 2.8 SD 0.7
Japuntich, 2006^6^ | Bupropion plus Counseling alone | Mean, 41 SD, 11.8 | White non-Hispanic, (82.6) | NS | <high school4 (2.8), High school/GED, 40 (27.8) Some college/tech school, 68 (47.2) College/graduate school, 31(21.5) | NR | F, (54.9) | | Cigarettes per day: mean, 22.1 SD, 10.2 FTND Test for Nicotine Dependence: mean, 5.5 SD, 4.4 CES-D for Depression: mean, 5.5 SD, 4.4
Japuntich, 2006^6^ | With CHESS SCRP | Mean, 40.6 SD, 12.4 | White non-Hispanic, (75.4) | NS | <High school, 5 (3.6) High school/GED, 41 (29.5) Some college/tech school, 72 (51.8) College/graduate school, 21 (15.1) | NR | F, (55.0) | | Cigarettes per day: mean, 21.1 SD, 9.5 FTND Test for nicotine dependence: mean, 5.4 SD, 2.1 CES-D for depression: mean, 5.2, SD, 4.7
Pattens, 2006^7^ | BOI | Mean, 15.8 SD, 1.4 | White non-Hispanic, (86) | NS | 6^th^–8^th^ grade, (9) 9^th^–11^th^ grade, (79) >12^th^ grade, (13) | NR | F, (49) | | Literacy--“easy to read English”: (81) Use of internet: little to no use (12) some use (41) a lot of use (48) Computer : at home (77) internet access (79)
Pattens, 2006^7^ | SOS | Mean, 15.7 SD, 1.3 | White non-Hispanic, (90) | NS | 6^th^–8^th^ grade, (16) 9^th^–11^th^ grade, (71) >12^th^ grade, (13) | NR | F, (50) | | Literacy--easy to read English: (86) Use of internet: little to no use (14) some use (33) a lot of use (53) Computer: in home (70) internet access (78)
Prochaska, 1993^8^ | Characteristics not reported by subgroup | NR | NR | NR | NR | NR | NR
Prokhorov, 2008^9^ | Clearing the Air self-help booklet | NR | NR | NR | NR | NR | NR | | Among nonsmokers, NonHispanic 291(58.1)
Prokhorov, 2008^9^ | ASPIRE CD-ROM | | | | | | | | Among nonsmokers, NonHispanic 244(42.6)
Schiffman, 2000^10^ | User Guide only | Mean, 41.7 SD, 13 | NS | Gross House Hold Income. USD mean, 38,000 SD, 22,300 | Mean, 13.5 yr SD, 2.1 | NR | F, (54.9) | | Previous cessation and nicotine replacement therapy experience : Previous quit attempt, ( 91.6) Prior nicotine patch use, (38.7) Prior nicotine gum use, (20.0) Smoking history (mean/SD): Cigarettes per day: 26.9/12.2 Yr of smoking: 23.1/12.6 Time of first cigarette (minutes): 14.6/31.7 No. of lifetime cessation attempts: 4.5/7.3 Initial motivation and confidence (mean/SD) (range, 1–5): Level of motivation: 4.3/0.7 Confidence of success: 3.9/1.0
Schiffman, 2000^10^ | CQP | Mean, 41 SD, 12.7 | NS | Gross House Hold Income, USD mean, 39800 SD, 22300 | Mean, 13.6 SD, 2.2 | NR | F, (53.4) | | Previous cessation and nicotine replacement therapy experience : Previous quit attempt, ( 91.8) Prior nicotine patch use, (34.9) Prior nicotine gum use,( 20.0) Smoking history (mean/SD): Cigarettes per day: 26.1/12.1 Yr of smoking: 22.3/12.4 Time of first cigarette (minutes): 16.8/27.1 No. of lifetime cessation attempts: 5.5/17.7 Initial motivation and confidence (mean/SD) (range, 1–5): Level of motivation: 4.3/0.8 Confidence of success: 4.0/1.0
Schiffman, 2000^10^ | Committed Quitter Program + Call | Mean, 41.7 SD, 12.9 | NS | Gross House Hold Income, USD mean, 39,100 SD, 22,200 | Mean, 13.6 SD, 2.1 | NR | F, (54.3) | | replacement therapy experience: Previous quit attempt, (90.9) Prior nicotine patch use, (35.1) Prior nicotine gum use, (20.2) Smoking history (mean/SD): Cigarettes per day: 26.0/12.1 Yr of smoking: 22.7/12.5 Time of first cigarette (minutes): 14.1/22.8 No. of lifetime cessation attempts: 5.8/18.7 Initial motivation and confidence (mean/SD) (range, 1–5): Level of motivation: 4.3/0.8 Confidence of success: 4.0/1.0
Schumann, 2006^11^ | Characteristics not reported by subgroup
Schumann, 2008^12^ | Assessment-only control group | Mean, 44.2 SD, 13.2 | NS | NS | <10 yr, 81 (26.2) 10 yr, 154 (49.8) >10 yr, 62 (20.1) | NR | | | Self-reported health status, score 0–100: mean, 74.2 SD, 17.2 Daily cigarette smoking: 245 (79.3) Cigarettes per day: mean, 15.4 SD, 8.9 Intention to quit within the next 6 months: 79 (32.2)
Schumann, 2008^12^ | Computer-tailored TTM-based intervention group | Mean, 44.8 SD, 14.6 | NS | NS | <10 yr, 77 (25.5) 10 yr, 156 (51.7) >10 yr, 54 (17.9) | NR | | | Self-reported health status, score 0–100: mean, 75.7 SD, 15.4 Daily cigarette smoking: 240 (79.5) Cigarettes per day: mean, 15 SD, 7.2 Intention to quit within the next 6 months: 48 (20.0)
Severson, 2008^13^ | Text-based website (Basic Condition) | Mean, 36.9 SD, 9.6 | White non-Hispanic, 1234(97.7) Black non-Hispanic, 15(1.2) Latino/Hispanic, 14(1.1) API, 4(0.3) AIAN, 17(1.3) | NS | <High school, 38(3.0) High school, 199(15.8) College, 548(43.4) >College 478(37.8) | NR | | | Self-efficacy: mean, 2.4 SD, 1 Readiness to quit: mean, 8.1 SD, 1.8 Currently smoking: 67 (5.3) Rural: 459 (36.6)
Strecher, 1994^14^ Study 1 | Characteristics not reported by subgroup
Strecher, 2005^15^ | Characteristics not reported by subgroup
Strecher, 2005^16^ | Control | Baseline characteristics not reported
Strecher, 2005^16^ | Tailored intervention | Baseline characteristics not reported
Strecher, 2006^17^ | Non-tailored web-based cessation material | Baseline characteristics not reported
Strecher, 2008^18^ | Low-tailored | Baseline characteristics not reported
Strecher, 2008^18^ | High tailored | Baseline characteristics not reported
Strecher, 2008^18^ | Tailored Web-based intervention (Enhanced Condition) | Mean, 36.7 SD, 9.7 | White non-Hispanic, 1228(97.5) Black non-Hispanic, 12(1) Latino/Hispanic, 17(1.3) API, 5(0.4) AIAN, 24(1.9) | NS | <High school, 28(2.2) High school, 208(16.5) College, 542(43.0) >College, 482(38.3) | NR | | | Self-efficacy: mean, 2.4 SD, 1 Readiness to quit: mean, 8.2 SD, 1.9 Currently smoking: 43 (3.4) Rural: 447 (35.7)
Strecher, 2008^18^ | CQPLAN
Swartz, 2006^19^ | 90 day wait period for access to website | Range, 18 to >70 | White non-Hispanic, 152(84.4) Black non-Hispanic, 9(5) Latino/Hispanic, 7(3.9) AIAN, 5(2.8) Other, (1.7) | NS | NS | NR | M, 88 (48.9) F, 92 (50.6) | | Cig/day: <16: 69 (38.6) 16–20: 56 (28.1) 21–30: 43 (24) 31+: 17 (9.4)
Swartz, 2006^19^ | Video-based internet site | Range, 18 to >70 | White non-Hispanic, 136(79.5) Black non-Hispanic, 14(8.2) Latino/Hispanic, 8(4.7) AIAN, 2(1.2) Other, 9 (5.3 ) | NS | NS | NR | M, 80 (46.8) F, 91 (53.2) | | Cig/day: <16: 55 (31.9) 16–20: 63(36.8) 21–30: 34 (20.2) 30+: 19 (11)

NR= Not Reported, NS= Not Significant, SD= Standard Deviation, SES= Socioeconomic Status, Yr= year, API = Asian Pacific Islander, AIAN = American Indian/Alaska Native, M= male, F = female, CQP = Committed Quitters Program, USD = United States Dollar

Reference List

1 An LC, Klatt C, Perry CL et al. The RealU online cessation intervention for college smokers: a randomized controlled trial. Prev Med 2008; 47(2):194–9.

2 Brendryen H, Drozd F, Kraft P. A digital smoking cessation program delivered through internet and cell phone without nicotine replacement (happy ending): randomized controlled trial. J Med Internet Res 2008; 10(5):e51.

3 Curry SJ, McBride C, Grothaus LC, Louie D, Wagner EH. A randomized trial of self-help materials, personalized feedback, and telephone counseling with nonvolunteer smokers. 1995; 63(6):1005–14.

4 Dijkstra A. Working mechanisms of computer-tailored health education: Evidence from smoking cessation. 2005; 20(5):527–39.

5 Haug S, Meyer C, Schorr G, Bauer S, John U. Continuous individual support of smoking cessation using text messaging: A pilot experimental study. Nicotine Tob Res 2009.

6 Japuntich SJ, Zehner ME, Smith SS et al. Smoking cessation via the internet: a randomized clinical trial of an internet intervention as adjuvant treatment in a smoking cessation intervention. Nicotine Tob Res 2006; 8 Suppl 1:S59–67.

7 Patten CA, Croghan IT, Meis TM et al. Randomized clinical trial of an Internet-based versus brief office intervention for adolescent smoking cessation. Patient Educ Couns 2006; 64(1–3):249–58.

8 Prochaska JO, DiClemente CC, Velicer WF, Rossi JS. Standardized, Individualized, Interactive, and Personalized Self-Help Programs for Smoking Cessation. 1993; 12(5):399–405.

9 Prokhorov AV, Kelder SH, Shegog R et al. Impact of A Smoking Prevention Interactive Experience (ASPIRE), an interactive, multimedia smoking prevention and cessation curriculum for culturally diverse high-school students. Nicotine Tob Res 2008; 10(9):1477–85.

10 Shiffman S, Paty JA, Rohay JM, Di Marino ME, Gitchell J. The efficacy of computer-tailored smoking cessation material as a supplement to nicotine polacrilex gum therapy. Arch Intern Med 2000; 160(11):1675–81.

11 Schumann A, John U, Rumpf H-J, Hapke U, Meyer C. Changes in the “stages of change” as outcome measures of a smoking cessation intervention: A randomized controlled trial. 2006; 43(2):101–6.

12 Schumann A, John U, Baumeister SE, Ulbricht S, Rumpf HJ, Meyer C. Computer-tailored smoking cessation intervention in a general population setting in Germany: outcome of a randomized controlled trial. Nicotine Tob Res 2008; 10(2):371–9.

13 Severson HH, Gordon JS, Danaher BG, Akers L. ChewFree.com: evaluation of a Web-based cessation program for smokeless tobacco users. Nicotine Tob Res 2008; 10(2):381–91.

14 Strecher VJ, Kreuter M, Den Boer D-J, Kobrin S, Hospers HJ, Skinner CS. The effects of computer-tailored smoking cessation messages in family practice settings. 1994; 39(3):262–70.

15 Strecher VJ, Marcus A, Bishop K et al. A randomized controlled trial of multiple tailored messages for smoking cessation among callers to the cancer information service. J Health Commun 2005; 10 Suppl 1:105–18.

16 Strecher VJ, Shiffman S, West R. Randomized controlled trial of a web-based computer-tailored smoking cessation program as a supplement to nicotine patch therapy. Addiction 2005; 100(5):682–8.

17 Strecher VJ, Shiffman S, West R. Moderators and mediators of a web-based computer-tailored smoking cessation program among nicotine patch users. Nicotine Tob Res 2006; 8 Suppl 1:S95–101.

18 Strecher VJ, McClure JB, Alexander GL et al. Web-based smoking-cessation programs: results of a randomized trial. Am J Prev Med 2008; 34(5):373–81.

19 Swartz LH, Noell JW, Schroeder SW, Ary DV. A randomised control study of a fully automated internet based smoking cessation programme. Tob Control 2006; 15(1):7–12.

Evidence table 16

Outcomes in studies addressing the impact of CHI applications on intermediate outcomes in alcohol abuse (KQ1b)

Author, year | Outcomes | Control Intervention | n | Measure at BL | Measure at Time point 2 | Measure at Time point 3 | Measure at Time point 4 | Measure at Final Time point | Ratios at Time points | Significance
Smoking
An, 2008^1^ | %abstinent for 30 days | Control | 260 | | 8 wks (%): 16.2 | 20 wks (%) 19.6 | | 30 weeks (%) 23.1 | | p<0.001
An, 2008^1^ | %abstinent for 30 days | RealU intervention | 257 | | 8 wks (%): 16 95 % CI: 0.64–1.66 | 20 wks (%) 24.1 95% CI: 0.88–2.04 | | 30 weeks (%) 40.5 95% CI: 1.58–3.40 | | p<0.001
Brendryen, 2008^2^ | Repeated Points of Abstinence (1 + 3 + 6 + 12 months) | Self-help booklet | 146 | | | | | 10(7) | | OR 3.43, P .002
Brendryen, 2008^2^ | | Happy Ending program (HE) | 144 | | | | | 29(20)
Curry, 1995^3^ | 7-day abstinence at 21 months | Control | 324 (119, 133, 72) | | | | | Precontemplation group (13), for contemplation group (11), for preparation group (18) | | .07. .95, .86
Curry, 1995^3^ | 7-day abstinence at 21 months | Booklet | 327 (125, 131, 71) | | | | | Precontemplation group (10), for contemplation group (10), for preparation group (15)
Curry, 1995^3^ | 7-day abstinence at 21 months | Feedback | 323 (128, 132, 63) | | | | | Precontemplation group (5), for contemplation group (12), for preparation group (16)
Curry, 1995^3^ | 7-day abstinence at 21 months | Phone | 150 (64, 64, 22) | | | | | Precontemplation group (16), for contemplation group (11), for preparation group (23)
Curry, 1995^3^ | Abstinent at 3, 12 and 21 months | Control | 324 (119, 133, 72) | | | | | Precontemplation group (1), for contemplation group (1), for preparation group (6) | | .03, .80, .56
Curry, 1995^3^ | Abstinent at 3, 12 and 21 months | Booklet | 327 (125, 131, 71) | | | | | Precontemplation group (0), for contemplation group (0.5), for preparation group (3)
Curry, 1995^3^ | Abstinent at 3, 12 and 21 months | Feedback | 323 (128, 132, 63) | | | | | Precontemplation group (1), for contemplation group (2), for preparation group (3)
Curry, 1995^3^ | Abstinent at 3, 12 and 21 months | Phone | 150 (64, 64, 22) | | | | | Precontemplation group (5), for contemplation group (2), for preparation group (9)
Dijkstra, 2005^4^ | Affective attitude | Standard | 51 | NR | | | | At time of intervention Mean, 5.61 | | P 0.048
Dijkstra, 2005^4^ | | Personalization | 50 | NR | | | | At time of intervention Mean, 5.13
Dijkstra, 2005^4^ | | Adaptation | 51 | NR | | | | At time of intervention Mean, 5.48
Dijkstra, 2005^4^ | | Feedback | 50 | NR | | | | At time of intervention Mean, 5.55
Dijkstra, 2005^4^ | Cognitive attitude | Standard | 51 | NR | | | | At time of intervention Mean, 2.62 | | P 0.028
Dijkstra, 2005^4^ | | Personalization | 50 | NR | | | | At time of intervention Mean, 2.52
Dijkstra, 2005^4^ | | Adaptation | 51 | NR | | | | At time of intervention Mean, 2.53
Dijkstra, 2005^4^ | | Feedback | 50 | NR | | | | At time of intervention Mean, 2.79
Dijkstra, 2005^4^ | Quitting attempts | Standard | NR | NR | | | | 4 months, (22.9) | | P 0.042
Dijkstra, 2005^4^ | | Personalization | NR | NR | | | | 4 months, (44.7)
Dijkstra, 2005^4^ | | Adaptation | NR | NR | | | | 4 months, (28.6)
Dijkstra, 2005^4^ | | Feedback | NR | NR | | | | 4 months, (48.5)
Hang, 2009^5^ | Number of cigarettes smoked per day | No intervention | 64 | Mean 11.7 SD 7.5 | | | | 3 months, Mean 9.5, SD 5.5
| Number of cigarettes smoked per day | SMS 1 per week | 50 | Mean 12.4 SD 7.3 | | | | 3 months, Mean 10.2, SD 6.5
| Number of cigarettes smoked per day | SMS 3 per week | 60 | Mean 11.2 SD 6.3 | | | | 3 months, Mean 9.7, SD 6.4 | | P .91
| 24 hour quit attempt | No intervention | 64 | | | | | 3 months, N 26, (41) | | P .47
| 24 hour quit attempt | SMS 1 per week | 50 | | | | | 3 months, N 20, (42)
| 24 hour quit attempt | SMS 3 per week | 60 | | | | | 3 months, N 30, (50)
Japuntich, 2006^6^ | Abstinent | Control | 144 | | 3 months (%): (20.8) | | | 6 mos (%):15 | | NR
Japuntich, 2006^6^ | Abstinent | CHESS SCRP | 140 | | 3 months (%): (22.9) OR: 1.13 (.64–1.98) | | | 6 mos (%):11.8 OR: 1.48 (.66–2.62)
Pattens, 2006^7^ | Smoking abstinence | Control | 69 | | 8 wks | 12 wks | | 24 wks (%): 12 95% CI: 5–22 | | 0.217
Pattens, 2006^7^ | Smoking abstinence | Internet based intervention | 70 | | 8 wks | 12 wks | | 24 wks (%): 6 95% CI: 2–14 | | 0.217
Prochaska, 1993^8^ | Point Prevalence Abstinence, Precontemplation stage | ALA+ (self-help manual) | | 0
Prochaska, 1993^8^ | Point Prevalence Abstinence, Precontemplation stage | TTT (individualized manual) | | 0
Prochaska, 1993^8^ | Point Prevalence Abstinence, Precontemplation stage | ITT (interactive computer report) | | 0
Prochaska, 1993^8^ | Point Prevalence Abstinence, Precontemplation stage | PITT (personalized counselor +TTT+ITT) | | 0
Prochaska, 1993^8^ | Point Prevalence Abstinence, Contemplation stage | ALA+ | | 0 | | | | (11.1)
Prochaska, 1993^8^ | Point Prevalence Abstinence, Contemplation stage | TTT | | 0 | | | | (5.0)
Prochaska, 1993^8^ | Point Prevalence Abstinence, Contemplation stage | ITT | | 0 | | | | (17.6)
Prochaska, 1993^8^ | Point Prevalence Abstinence, Contemplation stage | PITT | | 0 | | | | (5.3)
Prochaska, 1993^8^ | Point Prevalence Abstinence, Preparation stage | ALA+ | | 0 | | | | (10.8)
Prochaska, 1993^8^ | Point Prevalence Abstinence, Preparation stage | TTT | | 0 | | | | (15.4)
Prochaska, 1993^8^ | Point Prevalence Abstinence, Preparation stage | ITT | | 0 | | | | (25.0)
Prochaska, 1993^8^ | Point Prevalence Abstinence, Preparation stage | PITT | | 0 | | | | (15.6)
Prochaska, 1993^8^ | Point Prevalence Abstinence, Preparation stage | ALA+ | | 0 | | | | (11.6)
Prochaska, 1993^8^ | Point Prevalence Abstinence, Preparation stage | TTT | | 0 | | | | (29.4)
Prochaska, 1993^8^ | Point Prevalence Abstinence, Preparation stage | ITT | | 0 | | | | 28.0)
Prochaska, 1993^8^ | Point Prevalence Abstinence, Preparation stage | PITT | | 0 | | | | (27.9)
Prokhorov, 2008^9^ | Smoking initiation rates at 18 months (nonsmokers at BL) | Control (Clearing the Air self-help booklet) | 516 | | | | | (5.8) | | OR 2.9 Confidence interval 95% (1.1 7.8)
Prokhorov, 2008^9^ | Smoking initiation rates at 18 months (nonsmokers at BL) | ASPIRE CD-ROM | 582 | | | | | (1.9)
Prokhorov, 2008^9^ | Smoking cessation rates at 18 months (smokers at BL) | Control (Clearing the Air self-help booklet) | 34 | | | | | (61.8) | | OR 1.0 Confidence interval 95% (0.3 2.7)
Schiffman, 2000^10^ | Abstinence rates | Control | 1203 | | 28-day abstinence at 6 weeks (%): 28.6 95% CI: 1.780 (1.342–2.360) | | | 10-wks abstinence at 12 weeks: 18.9 95% CI: 2.044 (1.489–2.807) | | p≤0.001
Schiffman, 2000^10^ | Abstinence rates | Computer tailored smoking cessation materials (CQP) | 1217 | | 28- day abstinence at 6 wks: 41.6, 95% CI: 1.780 (1.342–2.360) | | | 10-wks abstinence at 12 wks: 32.3 95% CI: 2.044 (1.489–2.807) | | p≤0.001
Schumann, 2006^11^ | Average probability of progression (precontemplation and contemplation) | Control (no intervention) | 245 | | | | | 0.038
Schumann, 2006^11^ | Average probability of progression (precontemplation and contemplation) | Tailored letters | 240 | | | | | 0.032
Schumann, 2006^11^ | Average probability of regression (precontemplation and contemplation) | Control (no intervention) | 245 | | | | | 0.084
Schumann, 2006^11^ | Average probability of regression (precontemplation and contemplation) | Tailored letters | 240 | | | | | 0.034
Schumann, 2008^12^ | Point-prevalence abstinence | Control | 309 | | 6 mos: 46 | 12 mos: 55 | 18 mos: 55 | 24 mos: 69 | | NS
Schumann, 2008^12^ | Point-prevalence abstinence | Computer-tailored smoking cessation intervention | 302 | | 6 mos: 46 | 12 mos :56 | 18 mos: 55 | 24 mos: 63 | | NS
Schumann, 2008^12^ | Prolonged abstinence | Control | 309 | | | 12 mos: 38 | 18 ms: 46 | 24 mos: 46 | | NS
Schumann, 2008^12^ | Prolonged abstinence | Computer-tailored smoking cessation intervention | 302 | | | 12 mos: 35 | 18 mos: 45 | 24 mos: 46 | | NS
Severson, 2008^13^ | Tobacco abstinence (complete case) | Control | 100 | | 3 mos: 26.9 | 6 mos: 31 | | 3 and 6 mos: 21.2 | | Time point 2, 0.001 Time point 3, 0.001 Final Time point, 0.001
Severson, 2008^13^ | Tobacco abstinence (complete case) | Interactive, tailored web-based intervention | 159 | | 3 mos: 44.2 | 6 mos: 46.2 | | 3 and 6 mos: 40.6 | | Time point 2, 0.001 Time point 3, 0.001 Final Time point, 0.001
Severson, 2008^13^ | Tobacco abstinence (intent-to-treat) | Control | 100 | | 3 mos: 13.9 | 6 mos: 14.7 | | 3 and 6 mos: 7.9 | | Time point 2, 0.001 Time point 3, 0.001 Final time point, 0.001
Severson, 2008^13^ | Tobacco abstinence (intent-to-treat) | Interactive, tailored web-based intervention | 159 | | 3 mos: 19.5 | 6 mos: 19.3 | | 3 and 6 mos: 12.6 | | Time point 2, 0.001 Time point 3, 0.001 Final time point, 0.001
Severson, 2008^13^ | Smokeless tobacco use abstinence (complete case) | Control | 128 | | 3 mos: 32.4 | 6 mos: 35.3 | | 3 and 6 mos: 27.2 | | Time point 2, 0.001 Time point 3, 0.001 Final time point, 0.001
Severson, 2008^13^ | Smokeless tobacco use abstinence (complete case) | Interactive, tailored web-based intervention | 189 | | 3 mos: 49.6 | 6 mos: 51.3 | | 3 and 6 mos: 48.2 | | Time point 2, 0.001 Time point 3, 0.001 Final time point, 0.001
Severson, 2008^13^ | Smokeless tobacco use abstinence (intent-to-treat) | Control | 128 | | 3 mos: 16.8 | 6 mos: 16.8 | | 3 and 6 mos: 10.1 | | Time point 2, 0.001 Time point 3, 0.01 Final time point, 0.001
Severson, 2008^13^ | Smokeless tobacco use abstinence (intent-to-treat) | Interactive, tailored web-based intervention | 189 | | 3 mos: 21.9 | 6 mos: 21.4 | | 3 and 6 mos: 15.0 | | Time point 2, 0.001 Time point 3, 0.01 Final time point, 0.001
Strecher, 1994 14 <Study 1 | 7-day abstinence | Control (generic letter) | | | | | | (7.4) | | P <.10
Strecher, 1994 14 <Study 1 | 7-day abstinence | Tailored letter | | | | | | (20.8)
Strecher, 1994 14 <Study 1 | 7-day abstinence | Control (generic letter) / light smoker | | | | | | (7.1)
Strecher, 1994 14 <Study 1 | 7-day abstinence | Control (generic letter) / heavy smoker | | | | | | (7.7)
Strecher, 1994 14 <Study 1 | 7-day abstinence | Tailored letter / light smoker | | | | | | (30. 7)
Strecher, 1994 14 <Study 1 | 7-day abstinence | Tailored letter / heavy smoker | | | | | | (7.1)
Strecher, 1994 14 Study 1 | 7-day abstinence | Control (no letter) / light smoker | | | | | | (7.3) | | P < .05
Strecher, 1994 14 Study 1 | 7-day abstinence | Control (no letter) / heavy smoker | | | | | | (9.8)
Strecher, 1994 14 Study 1 | 7-day abstinence | Tailored letter / light smoker | | | | | | (19.1)
Strecher, 1994 14 Study 1 | 7-day abstinence | Tailored letter / heavy smoker | | | | | | (3.9)
Strecher, 2005^15^ | 7-day abstinence at 12 months (intent to treat analysis) | SU (single untailored booklet) | | | | | | (8.1) | | Difference between groups 3+4 and groups 1+2 (Wald Χ^2^ 4.7, p <.05; OR 1.41, 1.04 – 1.99)
Strecher, 2005^15^ | 7-day abstinence at 12 months (intent to treat analysis) | ST (single tailored booklet) | | | | | | (7.2)
Strecher, 2005^15^ | 7-day abstinence at 12 months (intent to treat analysis) | MT (multiple tailored materials) | | | | | | (10.3)
Strecher, 2005^15^ | 7-day abstinence at 12 months (intent to treat analysis) | MRT (multiple retailored materials) | | | | | | (10.5)
Strecher, 2005^15^ | 7-day abstinence at 12 months of subjects who were abstinent at 5 months (intent to treat analysis) | SU (single untailored booklet) | | | | | | (41.9) | | Difference between groups 3+4 and groups 1+2 (Wald Χ^2^ 1.4, p .2; OR 1.44, 0.78 – 2.68)
Strecher, 2005^15^ | 7-day abstinence at 12 months of subjects who were abstinent at 5 months (intent to treat analysis) | ST (single tailored booklet) | | | | | | (37.4)
Strecher, 2005^15^ | 7-day abstinence at 12 months of subjects who were abstinent at 5 months (intent to treat analysis) | MT (multiple tailored materials) | | | | | | (41.7)
Strecher, 2005^15^ | 7-day abstinence at 12 months of subjects who were abstinent at 5 months (intent to treat analysis) | MRT (multiple retailored materials) | | | | | | (53.6)
Strecher, 2005^15^ | 7-day abstinence at 12 months of subjects who were abstinent at 5 months (per protocol analysis) | SU (single untailored booklet) | | | | | | (57.1) | | Difference between groups 3+4 and groups 1+2 (Wald Χ^2^ 4.1, p < .05; OR 2.16, 1.03 – 4.65)
Strecher, 2005^15^ | 7-day abstinence at 12 months of subjects who were abstinent at 5 months (per protocol analysis) | ST (single tailored booklet) | | | | | | (51.4)
Strecher, 2005^15^ | 7-day abstinence at 12 months of subjects who were abstinent at 5 months (per protocol analysis) | MT (multiple tailored materials) | | | | | | (63.3)
Strecher, 2005^15^ | 7-day abstinence at 12 months of subjects who were abstinent at 5 months (per protocol analysis) | MRT (multiple retailored materials) | | | | | | (75.8)
Strecher, 2005^16^ | 28 day abstinence rate | Control | 588 | | 6 wks (%): 46.8 | | | 12 wks | | .008
Strecher, 2005^16^ | 28 day abstinence rate | CQ plan | 640 | | 6 wks (%): 54.4 OR: 1.36 95% CI: 1.08–1.70 | | | 12 wks | | .008
Strecher, 2005^16^ | 10 week continuous rates | Control | 418 | | 6 wks | | | 12 wks (%): 43.3 | | .0004
Strecher, 2005^16^ | 10 week continuous rates | CQ Plan | 446 | | 6 wks | | | 12 wks (%): 55.4 OR: 1.63 95% CI: 1.24–2.13 | | .0004
Strecher , 2006^17^ | Tobacco related illness | CQ-PLAN | 1491 | | 6 wks | | | 12 wks: 55.6 95% CI: | | p<0.001
Strecher , 2006^17^ | Tobacco related illness | CONTROL | 1491 | | 6 wks | | | 12 weeks: 38.2
Strecher , 2006^17^ | Non-smoking children in household | CQ PLAN | 1491 | | 6 wks | | | 12 wks: 57.7 | | p<0.001
Strecher , 2006^17^ | Non-smoking children in household | CONTROL | 1491 | | 6 wks | | | 12 wks: 38.5
Strecher , 2006^17^ | Frequency of alcohol consumption | CQ-PLAN | 1491 | | 6 wks | | | 12 wks: 55.4 | | p<0.001
Strecher , 2006^17^ | Frequency of alcohol consumption | CONTROL | 1491 | | 6 wks | | | 12 wks: 36.5
Strecher, 2008^18^ | Depth of efficacy expectation of smoking cessation intervention | High depth efficacy expectation | 466 | | | | | 6 mos follow up: 32.4 | | 0.213
Strecher, 2008^18^ | Depth of efficacy expectation of smoking cessation intervention | Low depth efficacy expectation | 478 | | | | | 6 mos follow up: 28.5 | | 0.213
Strecher, 2008^18^ | Depth of outcome expectation of smoking cessation intervention | High depth outcome expectation | 494 | | | | | 6 mos follow up: 32.2 | | Final time point, 0.242
Strecher, 2008^18^ | Depth of outcome expectation of smoking cessation intervention | Low depth outcome expectation | 450 | | | | | 6 mos follow up: 28.7 | | Final time point, 0.242
Strecher, 2008^18^ | Depth of success stories of smoking cessation intervention | High depth success story | 488 | | | | | 6 mos follow up: 34.3 | | Final time point, 0.018
Strecher, 2008^18^ | Depth of success stories of smoking cessation intervention | Low depth success story | 456 | | | | | 6 mos follow up: 26.8 | | Final time point, 0.018
Strecher, 2008^18^ | Personalization of message source | High personalization of message source | 481 | | | | | 6 mos follow up: 33.6 | | Final time point, 0.039
Strecher, 2008^18^ | Personalization of message source | Low personalization of message source | 463 | | | | | 6 mos follow up: 27.4 | | Final time point, 0.039
Strecher, 2008^18^ | Timing of message exposure | Multiple message exposure | 487 | | | | | 6 mos follow up: 29.6 | | Final time point 0.567
Strecher, 2008^18^ | Timing of message exposure | Ingle message exposure | 457 | | | | | 6 mos follow up: 31.3 | | Final time point 0.567
Swartz, 2006^19^ | Automated behavioral intervention for cessation of smoking at 90 day follow-up | Control | 9 | | | | | 90 day (%):8.2 | | 0.002
Swartz, 2006^19^ | Automated behavioral intervention for cessation of smoking at 90 day follow-up | Those who received immediate access to the web site for automated behavioral intervention for smoking | 21 | | | | | 90 day: 24.1 OR: 3.57 95% CI: 1.54–8.27 | | 0.002
Swartz, 2006^19^ | Automated behavioral intervention for cessation of smoking at 90 day follow-up | Control (intent to treat model) | 9 | | | | | 90 day: 5 | | 0.015
Swartz, 2006^19^ | Automated behavioral intervention for cessation of smoking at 90 day follow-up | behavioral intervention for smoking (intent to treat model) | 21 | | | | | 90 day: 12.3, OR: 2.66 95% CI: 1.18–5.99 | | 0.015

CI = confidence interval, NR = not reported, NS = not specified, OR = odd ratio, wks = weeks, mos = months

Reference List

1 An LC, Klatt C, Perry CL et al. The RealU online cessation intervention for college smokers: a randomized controlled trial. Prev Med 2008; 47(2):194–9.

2 Brendryen H, Drozd F, Kraft P. A digital smoking cessation program delivered through internet and cell phone without nicotine replacement (happy ending): randomized controlled trial. J Med Internet Res 2008; 10(5):e51.

3 Curry SJ, McBride C, Grothaus LC, Louie D, Wagner EH. A randomized trial of self-help materials, personalized feedback, and telephone counseling with nonvolunteer smokers. 1995; 63(6):1005–14.

4 Dijkstra A. Working mechanisms of computer-tailored health education: Evidence from smoking cessation. 2005; 20(5):527–39.

5 Haug S, Meyer C, Schorr G, Bauer S, John U. Continuous individual support of smoking cessation using text messaging: A pilot experimental study. Nicotine Tob Res 2009.

6 Japuntich SJ, Zehner ME, Smith SS et al. Smoking cessation via the internet: a randomized clinical trial of an internet intervention as adjuvant treatment in a smoking cessation intervention. Nicotine Tob Res 2006; 8 Suppl 1:S59–67.

7 Patten CA, Croghan IT, Meis TM et al. Randomized clinical trial of an Internet-based versus brief office intervention for adolescent smoking cessation. Patient Educ Couns 2006; 64(1–3):249–58.

8 Prochaska JO, DiClemente CC, Velicer WF, Rossi JS. Standardized, Individualized, Interactive, and Personalized Self-Help Programs for Smoking Cessation. 1993; 12(5):399–405.

9 Prokhorov AV, Kelder SH, Shegog R et al. Impact of A Smoking Prevention Interactive Experience (ASPIRE), an interactive, multimedia smoking prevention and cessation curriculum for culturally diverse high-school students. Nicotine Tob Res 2008; 10(9):1477–85.

10 Shiffman S, Paty JA, Rohay JM, Di Marino ME, Gitchell J. The efficacy of computer-tailored smoking cessation material as a supplement to nicotine polacrilex gum therapy. Arch Intern Med 2000; 160(11):1675–81.

11 Schumann A, John U, Rumpf H-J, Hapke U, Meyer C. Changes in the “stages of change” as outcome measures of a smoking cessation intervention: A randomized controlled trial. 2006; 43(2):101–6.

12 Schumann A, John U, Baumeister SE, Ulbricht S, Rumpf HJ, Meyer C. Computer-tailored smoking cessation intervention in a general population setting in Germany: outcome of a randomized controlled trial. Nicotine Tob Res 2008; 10(2):371–9.

13 Severson HH, Gordon JS, Danaher BG, Akers L. ChewFree.com: evaluation of a Web-based cessation program for smokeless tobacco users. Nicotine Tob Res 2008; 10(2):381–91.

14 Strecher VJ, Kreuter M, Den Boer D-J, Kobrin S, Hospers HJ, Skinner CS. The effects of computer-tailored smoking cessation messages in family practice settings. 1994; 39(3):262–70.

15 Strecher VJ, Marcus A, Bishop K et al. A randomized controlled trial of multiple tailored messages for smoking cessation among callers to the cancer information service. J Health Commun 2005; 10 Suppl 1:105–18.

16 Strecher VJ, Shiffman S, West R. Randomized controlled trial of a web-based computer-tailored smoking cessation program as a supplement to nicotine patch therapy. Addiction 2005; 100(5):682–8.

17 Strecher VJ, Shiffman S, West R. Moderators and mediators of a web-based computer-tailored smoking cessation program among nicotine patch users. Nicotine Tob Res 2006; 8 Suppl 1:S95–101.

18 Strecher VJ, McClure JB, Alexander GL et al. Web-based smoking-cessation programs: results of a randomized trial. Am J Prev Med 2008; 34(5):373–81.

19 Swartz LH, Noell JW, Schroeder SW, Ary DV. A randomised control study of a fully automated internet based smoking cessation programme. Tob Control 2006; 15(1):7–12.

Evidence Table 17

Description of RCTs addressing the impact of CHI applications on intermediate outcomes in obesity (KQ1b)

Author, year | Consumer under study | CHI Application type | Location | Year data collected/ duration of intervention | Inclusion criteria | Exclusion criteria | Control | Intervention | Jadad score
Obesity
Booth, 2008^1^ | Individuals interested in their own health care | Personal monitoring device | NS | NS | BMI was between 24.5 and 37 kg/ m2, Internet access | <18 yr, Pregnant or lactating or were currently receiving medications for Type 1 or Type 2 diabetes | | ED group EX group
Burnett, 1985 2 Obesity | Overweight females | An interactive lap sized computer | Home / Res | Ns | Consenting 30 – 50 yr old females to the newspaper advertisement | Ns | Paper and pencil method of providing feedback | Computer Assisted method of providing feedback
Cussler, 2008^3^ | Individuals interested in their own health care | Interactive consumer website | NS | NS | 40 – 55 yr, Women, have a BMI between 25.0 and 38.0 kg/m2, Nonsmoker and be free from major illnesses, Internet access | | Self directed group | Internet group | 2
Frenn, 2005 4 Obesity | Students of 7th grade | Computer based interactive web | Computer labs in school | NR | 7th grade student who could read in English / Spanish and completed the consent form | ns | Regular Classroom assignments | 8 sessions Internet based interactive model based on HP/TM
Hunter, 2008^5^ | Individuals interested in their own health care | Interactive consumer website | NS | 2006 | 18 – 65 yr, Weight within 5 pounds or above their maximum allowable weight for the USAF, Personal computer with Internet access, plans to remain in the local area for 1 year | Lost more than 10 pounds in the previous 3 months, Used prescription or over-the-counter weight-loss medications in the previous 6 months, had any physical activity restrictions, had a history of myocardial infarction, stroke, or cancer in the last 5 years, reported diabetes, angina, or thyroid difficulties; or had orthopedic or joint problems, Women were excluded if they were currently pregnant or breast-feeding, or had plans to become pregnant in the next year | Usual care | Behavioral Internet treatment | 2.5
Kroeze, 2008^6^ | Individuals interested in their own health care | Interactive consumer website | Worksites and 2 neighborhoods in the urban area of Rotterdam | 2003–2004 | 18–65 yr, Sufficient understanding of the Dutch language, No diet prescribed by a dietitian or physician, and no treatment for hypercholesterolemia | | Generic condition | Interactive-tailored condition Print-tailored condition | 3
McConnon, 2007^7^ | Individuals interested in their own health care | Interactive consumer website | Home/ residence | 2003/ NS | 18 – 65 yr, BMI 30 or more, able to access internet at least 1 time a week, able to read and write English | | Usual care | Internet group | 1
Taylor, 1991^9^ | Overweight women | Pocket Computer Device | Home / Res | NS | Overweight women BMi b/w 25 and 35 kg/m^3 | Bulemia, Depression, alcohol and drug dependence, psychosis, DSM III R | Computer Assisted Therapy (CAT) | 1200 calorie diet followed by CAT
Williamson, 2006^10^ | Individuals interested in their own health care | Interactive consumer website | Clinician office | NS | 11 – 15 yr, African-American, Female, BMI above the 85th percentile for age and gender based on 1999 National Health and Nutrition Examination Study normative data, at least one obese biological parent, as defined by BMI > 30, one designated parent who was overweight (BMI > 27), adolescent’s family was willing to pay $300 out-of pocket expenses toward the purchase of the computer worth >$1000, the family home had electricity and at least one functional telephone line | | Control and intervention adolescents | Control and intervention parents | 2
Womble , 2004^11^ | Individuals interested in their own health care | Interactive consumer website | NS | 2001/ NS | 18–65 yr, BMI: 27–40 kg/m2, Daily access to the internet | Type 1 or 2 diabetes, Uncontrolled HTN (BP>140/90), History of cerebrovascular, cardiovascular, kidney or liver disease, Use of medications known to affect body weight, pregnancy or lactation weight loss>=5% of initial weight, Use of anorectic agents in the previous 6 months, bulimia, major depression, or other psychiatric illness significantly disrupted daily functioning | | | 0.5

NS = not specified, yr = year, BMI = body mass index, kg/m2 = Kilograms per square meter, BP = blood pressure, HTN = hypertension

Reference List

1 Booth AO, Nowson CA, Matters H. Evaluation of an interactive, Internet-based weight loss program: a pilot study. Health Educ Res 2008; 23(3):371–81.

2 Burnett KF, Taylor CB, Agras WS. Ambulatory computer-assisted therapy for obesity: A new frontier for behavior therapy. 1985; 53(5):698–703.

3 Cussler EC, Teixeira PJ, Going SB et al. Maintenance of weight loss in overweight middle-aged women through the Internet. Obesity (Silver Spring) 2008; 16(5):1052–60.

4 Frenn M, Malin S, Brown RL et al. Changing the tide: An Internet/video exercise and low-fat diet intervention with middle-school students. 2005; 18(1):13–21.

5 Hunter CM, Peterson AL, Alvarez LM et al. Weight management using the internet a randomized controlled trial. Am J Prev Med 2008; 34(2):119–26.

6 Kroeze W, Oenema A, Campbell M, Brug J. The efficacy of Web-based and print-delivered computer-tailored interventions to reduce fat intake: results of a randomized, controlled trial. J Nutr Educ Behav 2008; 40(4):226–36.

7 McConnon A, Kirk SF, Cockroft JE et al. The Internet for weight control in an obese sample: results of a randomised controlled trial. BMC Health Serv Res 2007; 7:206.

8 Morgan PJ, Lubans DR, Collins CE, Warren JM, Callister R. The SHED-IT Randomized Controlled Trial: Evaluation of an Internet-based Weight-loss Program for Men. Obesity (Silver Spring) 2009.

9 Taylor CB, Agras WS, Losch M, Plante TG, Burnett K. Improving the effectiveness of computer-assisted weight loss. 1991; 22(2):229–36.

10 Williamson DA, Walden HM, White MA et al. Two-year internet-based randomized controlled trial for weight loss in African-American girls. Obesity (Silver Spring) 2006; 14(7):1231–43.

11 Womble LG, Wadden TA, McGuckin BG, Sargent SL, Rothman RA, Krauthamer-Ewing ES. A randomized controlled trial of a commercial internet weight loss program. Obes Res 2004; 12(6):1011–8.

Evidence Table 18

Description of consumer characteristics in studies addressing the impact of CHI applications on intermediate outcomes in obesity (KQ1b)

Author, year | Control Interventions | Age | Race, n(%) | Income | Education, n(%) | SES | Gender, n(%) | Marital Status | Other outcomes
Obesity
Booth, 2008^1^ | Comparison | NS | NS | NS | NS | NR | NS | NS | BMI: mean, 29 SD, 2.3 Weight (kg): mean, 80.5 SD, 8.6
Booth, 2008^1^ | Online Diet advice and exercise program | Mean, 46.4 SD, 12.5 | NS | NS | NS | NR | NS | NS | BMI: mean, 29.9 SD, 2.7 Weight (kg): mean, 84.3 SD, 11.3
Booth, 2008^1^ | Online exercise program only | Mean, 46.2 SD, 9.2 | NS | NS | NS | NR | NS | NS | BMI: mean, 30.1 SD, 3.4 Weight (kg) mean, 82 SD, 10.8
Burnett, 1985 2 Obesity | Paper and Pencil method of providing feedback | 39.8 SD 5.5 | Ns | Ns | Ns | Ns | All F
Burnett, 1985 2 Obesity | A lap sized computer | 43.2 SD 8.8 | | | | | All F
Cussler, 2008^3^ | Self directed group | Mean, 48.2 SD, 4.2 | NS | NS | NS | NR | NR | NR | Weight (kg): mean, 82 SD, 10.8 BMI: mean, 30.1 SD, 3.4
Cussler, 2008^3^ | Internet group | Mean, 48.3 SD, 4.4 | NS | NS | NS | NR | NR | NR | Weight(kg): mean, 84.4 SD, 12.6 BMI: mean, 30.6 SD, 3.9
Frenn, 2005 4 Obesity | Regular Classroom Assignments | 12—14yrs | Diet : Asians 2 (4.1); Blacks 15 (30.6); Hispanics 17 (34.7); Native Americans 4 (8.2); Whites 4 (8.2); Others 7 (14.3) Activity: Asians 3 (5); Blacks 16 (26.7); Hispanics 24 (40); Native Americans 4 (6.5); Whites 4 (8.9); Others 9 (15) | Diet: Free lunch 35(71.4); Reduced 6(12.2); No reduction 8(16.0) Activity: Free lunch 42(70.0); Reduced 8(13.3); No reduction 10(16.7) | Seventh grade Students | NR | Diet: M 22 (44.9) F 27 (55.1); Activity: M 30 (50) F 30 (50)
Frenn, 2005 4 Obesity | 8 sessions Internet based interactive model based on HP/TM | | Diet: Asians 0 (0); Blacks 8 (20); Hispanics 22 (55); Native Americans 1 (2.5); Whites 5 (12.5); Others 4 (10) Activity: Asians 0 (0); Blacks 9 (20.9); Hispanics 23 (53.3); Native Americans 0 (0); Whites 4 (9.3); Others 7 (16.3) | Diet: Free lunch 30(75.0); Reduced 5(12.5); No reduction 5(12.5) Activity: Free lunch 31 (72.1); Reduced 6(14); No reduction 6 (14) | | | Diet group: M 12(30); F 28(70) Activity: M 14 (26.3) F 29 (73.7)
Hunter, 2008^5^ | Usual care | Mean, 34.4 SD, 7.2 | C, 222 C, 53.2 | NS | 12–16 years, 222(61.7) | NR | F, 222(50.5) | NR
Hunter, 2008^5^ | Behavioral Internet treatment | Mean, 33.5 SD, 7.4 | C, 224 C, 58.0 | NS | 12–16 years, 224(63.9) | NR | F, 224(50.0) | NR
Kroeze, 2008 6 | Generic condition | Mean, 44.1 SD, 9.7 | NS | NS | Elementary,3(2) Lower secondary, 28(18.4) Higher secondary, 56(37.4) Tertiary, 63(42.2) | NR | F,150(56.0) | NR | BMI (kg/m2): mean, 25.3 SD, 3.8
Kroeze, 2008 6 | Interactive-tailored condition | Mean, 44 SD, 10.56 | NS | NS | Elementary,4(2.6) Lower secondary,29(19.2) Higher secondary,51( 33.8) Tertiary, 67(44.4) | NR | F,151(53.6) | NR | BMI (kg/m2): mean, 25.5 SD, 3.8
Kroeze, 2008 6 | Print-tailored condition | Mean, 43.4 SD, 10.1 | NS | NS | Elementary,15(3.6) Lower secondary,26(18.6) Higher secondary,49(35.0) Tertiary,61(42.9) | NR | F,141(55.3) | NR | BMI (kg/m2): mean, 25.5 SD, 4.3
McConnon, 2007^7^ | Usual care | Mean, 47.4 | NS | NS | NS | NR | NR | NR | Weight (kg): mean, 94.9 BMI: mean, 34.4 Quality of Life (Euro QoL): mean, 61.5 Physical Activity (Baecke): mean, 6.7
McConnon, 2007^7^ | Internet group | Mean, 48.1 | NS | NS | NS | NR | NR | NR | Weight (kg): mean, 97.5 BMI: mean, 34.35 Quality of Life (EuroQoL): mean, 70 Physical Activity (Baecke): mean, 6.8
Morgan, 2009 8 Obesity | One information session + Program booklet | 34 SD 11.6 | NS | NS | Student: 14 Non Acad Staff: 13 Acad Staff: 4 | Measured by SEIFA score 1,2-0 3,4–5 5,6–9 7,8:11 9,10:3 | All M
Morgan, 2009 8 Obesity | SHED IT internet program w/ information session and program booklet (the program facilitates self monitoring and daily diary to which the researchers respond) | 37.5 SD 10.4 | NS | NS | Student: 14 Non Acad Staff: 14 Acad Staff: 6 | 1,2-1 3,4–7 5,6-3 7,8:11 9,10:2 | All M
Taylor, 1991 9 Obesity | Computer Assisted Therapy | 43.7. SD 11.1 | NS | NS | NS | NS | All F
Taylor, 1991 9 Obesity | 1200 calorie diet (Frozen Food) followed by CAT
Williamson, 2006^10^ | Control and intervention adolescents | Mean, 13.2 SD, 1.4 | NS | NS | NS | NR | NR | NR | Height (cm): mean, 160.0 SD, 8.1 Weight (kg): mean, 93.3 SD, 22.5 BMI: percentile 98.3 (2.5) mean, 36.4 SD, 7.9body fat DXA: mean, 45.9 SD, 7.5
Williamson, 2006^10^ | Control and intervention parents | Mean, 43.2 SD, 6.2 | NS | NS | NS | NR | NR | NR | Height (cm): mean, 162.3 SD, 6.9 Weight (kg): mean, 101.2 SD, 18.4 BMI: percentile not reportedmean, 38.4 SD, 7.2 Body fat DXA: mean, 48.4 SD, 6.3
Womble, 2004^11^ | Control | Mean, 43.3 SD, 11.1 | NS | NS | NS | NR | NR | NR | Height (cm): mean, 162.8 SD, 6.3 Weight (kg): mean, 87.9 SD, 10.8 BP(systolic): mean,112.1 SD, 13.8 BP (diastolic): mean, 66 SD, 9.6 Glucose: mean, 81.5 SD, 21.3
Womble, 2004^11^ | ediets.com | Mean, 44.2 SD, 9.3 | NS | NS | NS | NR | NR | NR | Height (cm): mean, 165.5 SD, 6.5 Weight (kg): mean, 93.4 SD, 12.6 BP (systolic): mean, 121.7 SD, 16.7 BP (diastolic): mean, 74.4 SD, 10.1 Glucose: mean, 90.2 SD, 11.7

C = Caucasian, NS = not specified, NR = not reported, F = female, kg = kilograms, BMI = body mass index, cm = centimeter, BP = blood pressure, kg/m2 = kilograms per square meter, SD = standard deviation, SES = Socio economic status

Reference List

1 Booth AO, Nowson CA, Matters H. Evaluation of an interactive, Internet-based weight loss program: a pilot study. Health Educ Res 2008; 23(3):371–81.

2 Burnett KF, Taylor CB, Agras WS. Ambulatory computer-assisted therapy for obesity: A new frontier for behavior therapy. 1985; 53(5):698–703.

3 Cussler EC, Teixeira PJ, Going SB et al. Maintenance of weight loss in overweight middle-aged women through the Internet. Obesity (Silver Spring) 2008; 16(5):1052–60.

4 Frenn M, Malin S, Brown RL et al. Changing the tide: An Internet/video exercise and low-fat diet intervention with middle-school students. 2005; 18(1):13–21.

5 Hunter CM, Peterson AL, Alvarez LM et al. Weight management using the internet a randomized controlled trial. Am J Prev Med 2008; 34(2):119–26.

6 Kroeze W, Oenema A, Campbell M, Brug J. The efficacy of Web-based and print-delivered computer-tailored interventions to reduce fat intake: results of a randomized, controlled trial. J Nutr Educ Behav 2008; 40(4):226–36.

7 McConnon A, Kirk SF, Cockroft JE et al. The Internet for weight control in an obese sample: results of a randomised controlled trial. BMC Health Serv Res 2007; 7:206.

8 Morgan PJ, Lubans DR, Collins CE, Warren JM, Callister R. The SHED-IT Randomized Controlled Trial: Evaluation of an Internet-based Weight-loss Program for Men. Obesity (Silver Spring) 2009.

9 Taylor CB, Agras WS, Losch M, Plante TG, Burnett K. Improving the effectiveness of computer-assisted weight loss. 1991; 22(2):229–36.

10 Williamson DA, Walden HM, White MA et al. Two-year internet-based randomized controlled trial for weight loss in African-American girls. Obesity (Silver Spring) 2006; 14(7):1231–43.

11 Womble LG, Wadden TA, McGuckin BG, Sargent SL, Rothman RA, Krauthamer-Ewing ES. A randomized controlled trial of a commercial internet weight loss program. Obes Res 2004; 12(6):1011–8.

Evidence table 19

Outcomes in studies addressing the impact of CHI application intermediate outcomes in obesity (KQ1b)

Author, year | Outcomes | Control Intervention | n | Measure at BL | Measure at time point 2 | Measure at time point 3 | Measure at time point 4 | Measure at final time point | ratios at time points | Significance
Obesity
Booth, 2008^1^ | Weight change (%) | EX | 26 | | | | | 12weeks: mean, 2.1 range, −2.9–14.2 SD, 3.4
Booth, 2008^1^ | Weight change (%) | ED | 27 | | | | | 12weeks: mean, 0.9 range, 3.0–8.6 SD, 2.5
Booth, 2008^1^ | Waist circumference change (cm) | EX | 26 | | | | | 12weeks mean, −4.5 range, −12.5–4.7 SD, 4.5
Booth, 2008^1^ | Waist circumference change (cm) | ED | 27 | | | | | 12weeks mean, −3.2 range, −8.7–2.2 SD, 2.9
Booth, 2008^1^ | Physical activity (daily steps) | EX | 26 | Mean, 9151.5 range, 3559,16623 SD, 3289.9 | | | | 12weeks mean, 12299.6 range, 6214,19246 SD, 3514.7
Booth, 2008^1^ | Physical activity (daily steps) | ED | 27 | Mean, 8673.3 range, 2784,15202 SD, 3567.3 | | | | 12weeks mean, 12198.8 range, 6650,22572 SD, 4121.8
Booth, 2008^1^ | Energy intake | EX | 26 | | | | | 12weeks mean, 131.1 SD, 759.9 | | BL, time point 2, difference between group p 0.066
Booth, 2008^1^ | Energy intake | ED | 27 | | | | | 12weeks mean, −1812.6 SD, 729.9
Burnett, 1985^2^ Obesity | Short term weight change: Baseline 2 wk period | Paper and pencil method of providing feedback | 6 | Gain of weight: 0.67lbs SD 2.66lbs | | | | | | The initial 2 week period had only self monitoring and instruction to lose wt given
Burnett, 1985^2^ Obesity | Short term weight change: Baseline 2 wk period | Computer Assisted method of providing feedback | 6 | Gain of weight: 0.17lbs SD 0.41lbs | | | | | | The initial 2 week period had only self monitoring and instruction to lose wt given
Burnett, 1985^2^ Obesity | Short term weight change: Post-baseline 8 wk period | Paper and pencil method of providing feedback | 6 | Loss of weight: 3.3 lbs SD 3.2 lbs | | | | | | The Rx→Withdraw→Rx phase 2 + 2 + 4 wk format.
Burnett, 1985^2^ Obesity | Short term weight change: Post-baseline 8 wk period | Computer Assisted method of providing feedback | 6 | Loss of weight: 8.1 lbs SD 2.7 lbs | | | | | | The Rx→Withdraw→Rx phase 2 + 2 + 4 wk format.
Burnett, 1985^2^ Obesity | Long term weight changes (24 wks) | Paper and pencil method of providing feedback | 6 | Loss of Weight: 4.17 lbs SD 4.83 lbs | | | | | | No treatment offered during this time
Burnett, 1985^2^ Obesity | Long term weight changes (24 wks) | Computer Assisted method of providing feedback | 6 | Loss of Weight: 15.67lbs SD 10.46 lbs | | | | | | No treatment offered during this time
Burnett, 1985^2^ Obesity | Long term weight changes (40 wks) | Paper and pencil method of providing feedback | 6 | Loss of Weight: 2.34 lbs SD 7.31 | | | | | | No treatment offered during this time
Burnett, 1985^2^ Obesity | Long term weight changes (40 wks) | Computer Assisted method of providing feedback | 6 | Loss of Weight: 17.67 lbs SD 13.82 lbs | | | | | | No treatment offered during this time
Burnett, 1985^2^ Obesity | Self-reported Caloric intake | Paper and pencil method of providing feedback | 6 | 2076 cal SD 165 cal | | | | 1462 cal SD 324 cal
Burnett, 1985^2^ Obesity | | Computer Assisted method of providing feedback | 6 | 1942 cal SD 334 cal | | | | 1142 cal SD 323 cal
Burnett, 1985^2^ Obesity | Self-reported physical activity | Paper and pencil method of providing feedback | 6 | 77 PA units SD 128 | | | | 206 PA units SD 108
Burnett, 1985^2^ Obesity | | Computer Assisted method of providing feedback | 6 | 172 PA units SD 188 | | | | 372 PA units SD 158
Burnett, 1985^2^ Obesity | How beneficial will this treatment be in promoting weight loss for you? | Paper and pencil method of providing feedback | 6 | | | | | 2.72 SD 0.58
Burnett, 1985^2^ Obesity | | Computer Assisted method of providing feedback | 6 | | | | | 2.79 SD 0.94
Burnett, 1985^2^ Obesity | How beneficial will this treatment be in promoting weight loss for overwt indi.? | Paper and pencil method of providing feedback | 6 | | | | | 2.84 SD 0.54
Burnett, 1985^2^ Obesity | | Computer Assisted method of providing feedback | 6 | | | | | 2.74 SD 0.84
Cussler, 2008^3^ | Weight change (kg) | Control | 59 | Mean, −5.2 SD, 3.8 | | | | 4–16months: mean, 1 SD, 4.6
Cussler, 2008^3^ | Weight change (kg) | Internet group | 52 | Mean, −5.3 SD, 3.6 | | | | 4–16months: mean, 0.7 SD, 5.4
Cussler, 2008^3^ | BMI | Control | 59 | Mean, −1.9 SD, 1.4 | BL-4 months | | | 4–16months mean, 1.9 SD, 1.5
Cussler, 2008^3^ | BMI | Internet | 52 | Mean, −1.9 SD, 1.4 | BL-4 months | | | 4–16months mean, −2.1 SD, 1.4
Cussler, 2008^3^ | Exercise energy expenditure (kcal/day) | Control | 59 | mean, 144 SD, 151 | BL-4 months | | | 4–16months mean, 164 SD, 268
Cussler, 2008^3^ | Exercise energy expenditure (kcal/day) | Internet | 52 | Mean, 151 SD, 196 | BL-4 months | | | 4–16months mean, 123 SD, 265
Cussler, 2008^3^ | Energy intake (kcal/day) | Control | 59 | Mean, −370 SD, 471 | BL-4 months | | | 4–16months mean, 91 SD, 330
Cussler, 2008^3^ | Energy intake (kcal/day) | Internet | 52 | | BL-4months | | | 4–16months mean, 74 SD, 371 | | BL, time point 2, change in energy intake
Frenn, 2005 4 Obesity | Physical Activity | Regular Classroom assignments | 60 | Reduction in moderate/vigorous PA by 46 min measured by the log
Frenn, 2005 4 Obesity | | 8 sessions Internet based interactive model based on HP/TM | 43 | Increase in the PA by 22 min for those completing 2/3 modules and 33 min for those completing all 3 modules (p=0,05)
Frenn, 2005 4 Obesity | Diet | Regular Classroom assignments | 49 | Fat intake went from 31.5 → 31.6% (Not significant)
Frenn, 2005 4 Obesity | Diet | 8 sessions Internet based interactive model based on HP/TM | 40 | Reduced fat intake from 30.7 to 29.9% (p=0,008)
Hunter, 2008^5^ | Body weight (kg) | Control | 222 | Mean, 86.6 SD, 14.7 | | | | 6months: mean, 87.4 SD, 14.7
Hunter, 2008^5^ | Body weight (kg) | BIT | 224 | Mean, 87.4 SD, 15.6 | | | | 6months: mean, 85.5 SD, 15.8
Hunter, 2008^5^ | BMI (kg/m2) | Control | 222 | Mean, 29.3 SD, 3 | | | | 6months mean, 29.4 SD, 3
Hunter, 2008^5^ | BMI (kg/m2) | BIT | 224 | mean, 29.4 SD, 3 | | | | 6months mean, 28.8 SD, 3.3
Hunter, 2008^5^ | Waist circumference (cm) | Control | 222 | Mean, 94.2 SD, 10.9 | | | | 6months mean, 93.4 SD, 12.8
Hunter, 2008^5^ | Waist circumference (cm) | BIT | 224 | Mean, 94.5 SD, 11 | | | | 6months mean, 92.2 SD, 11.6
Hunter, 2008^5^ | Body fat percentage (%) | Control | 222 | Mean, 34.2 SD, 6.9 | | | | 6months mean, 34.7 SD, 7
Hunter, 2008^5^ | Body fat percentage (%) | BIT | 224 | | | | | 6months mean, 33.9 SD, 7.3
Kroeze, 2008^6^ | Total fat intake | Control | 133 | g | 1month mean, 88.4 SD, 39.9 | | | 6months: mean, 83.0 SD, 34.2
Kroeze, 2008^6^ | Total fat intake | Interactive-tailored condition | 126 | g | 1 month mean, 77.4 SD, 30.9 | | | 6months: mean, 77.9 SD, 30.4
Kroeze, 2008^6^ | Total fat intake | Print-tailored condition | 124 | g | 1 month mean, 80.5 SD, 25.7 | | | 6months: mean, 76.1 SD, 26.9
Kroeze, 2008^6^ | Saturated fat intake | Control | 133 | g | 1 month mean, 31.4 SD, 15 | | | 6months mean, 29.5 SD, 13.7
Kroeze, 2008^6^ | Saturated fat intake | Interactive Condition | 126 | g | 1 month mean, 28.3 SD, 12.9 | | | 6months mean, 28.5 SD, 10
Kroeze, 2008^6^ | Saturated fat intake | Print condition | 124 | g | 1 month mean, 28.9 SD, 9.8 | | | 6months mean, 27.0 SD, 10
Kroeze, 2008^6^ | Energy intake | Control | 133 | mega joules | 1 month mean, 9.4 SD, 3.1 | | | 6months mean, 8.9 SD, 3
Kroeze, 2008^6^ | Energy intake | Interactive Condition | 126 | mega joules | 1 month mean, 8.6 SD, 2.5 | | | 6months mean, 8.4 SD, 2.5
Kroeze, 2008^6^ | Energy intake | Print condition | 124 | mega joules | 1 month mean, 8.3 SD, 2.7 | | | 6months mean, 8.2 SD, 2.4
McConnon, 2007^7^ | BMI change at 12 months (kg/m2) | Control | 77 | kg / m2 | | | | 12 months after baseline: range, −8.1 to +3.5;
McConnon, 2007^7^ | BMI change at 12 months (kg/m2) | Internet group | 54 | kg / m2 | | | | 12 months after baseline: range, −5.9 to 3.8;
McConnon, 2007^7^ | Loss of 5% or more body weight (12 months) | Control | 77 | | | 6 months | | 12 months (%):(18)
McConnon, 2007^7^ | Loss of 5% or more body weight (12 months) | Internet group | 54 | | | 6 months | | 12 months (%): (22)
McConnon, 2007^7^ | Using website at 6 months, at 12 months | Internet group | 54 | | mean, 53 | 6 months | | 12 months (%): (29)
McConnon, 2007^7^ | Never used website | Internet group | 54 | | | 6 months | | 12 months (%): (47)
McConnon, 2007^7^ | Of those who used website, found it easy / very easy | Internet group | 54 | | mean, 63 | 6 months | | 12 months (%): (85)
McConnon, 2007^7^ | Of those who us website, found it clear / very clear | Internet group | 54 | | mean, 78 | 6 months | | 12 months (%): (76)
Morgan, 2009^8^ Obesity | Change in body wt. 3m | Prog info + Booklet gp | 31 | Loss of Weight: −3.0 (−4.5, −1.4) KG | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Change in body wt. 3m | SHED IT group | 34 | Loss of Weight: −4.8 (−6.4, −3.3) KG | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Change in body wt. 6m | Prog info + Booklet gp | 31 | Loss of Weight: −3.5 (−5.5, −1.4) | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Change in body wt. 6m | SHED IT group | 34 | Loss of Weight: −5.3 (−7.3, −3.3) | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Waist circumference (cm) 3m | Prog info + Booklet gp | 31 | LOSS: −4.4 (−6.3, −2.5) CM | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Waist circumference (cm) 3m | SHED IT group | 34 | LOSS: −5.2 (−7.1, −3.4) CM | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Waist circumference (cm) 6m | Prog info + Booklet gp | 31 | −5.6 (−7.7, −3.5) CM | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Waist circumference (cm) 6m | SHED IT group | 34 | −7.0 (−9.1, −4.9) CM | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | BMI (kg/m_2_) 3m | Prog info + Booklet gp | 31 | −0.9 (−1.4, −0.5) KG/M^2 | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | BMI (kg/m_2_) 3m | SHED IT group | 34 | −1.5 (−2.0, −1.0) KG/M^2 | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | BMI (kg/m_2_) 6m | Prog info + Booklet gp | 31 | −1.1 (1.7, −0.5) | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | BMI (kg/m_2_) 6m | SHED IT group | 34 | −1.6 (−2.2, −1.0) | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Systolic blood pressure 3m | Prog info + Booklet gp | 31 | −8 (−12, −3) MM HG | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Systolic blood pressure 3m | SHED IT group | 34 | −6 (−10, −1) MM HG | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Systolic blood pressure 6m | Prog info + Booklet gp | 31 | −10 (−14, −6) | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Systolic blood pressure 6m | SHED IT group | 34 | −10 (−14, −7) | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Diastolic blood pressure 3m | Prog info + Booklet gp | 31 | −6 (−10, −2) MM HG | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Diastolic blood pressure 3m | SHED IT group | 34 | −4 (−8, −1) MM HG | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Diastolic blood pressure 6m | Prog info + Booklet gp | 31 | −5 (−10, −2) | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Diastolic blood pressure 6m | SHED IT group | 34 | −6 (−11, −1) | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Resting heart rate 3m | Prog info + Booklet gp | 31 | −7 (−11, −3) BPM | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Resting heart rate 3m | SHED IT group | 34 | −9 (−12, −5) BPM | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Resting heart rate 6m | Prog info + Booklet gp | 31 | −7 (−12, −3) BPM | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Resting heart rate 6m | SHED IT group | 34 | −6 (−11, −2) BPM | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Physical activity (mean steps/day) 3m | Prog info + Booklet gp | 31 | Went Up by: 976 (−12, 1,965) STEPS/DAY | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Physical activity (mean steps/day) 3m | SHED IT group | 34 | Went Up by: 1,184 (234, 2,133) STEP/DAY | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Physical activity (mean steps/day) 6m | Prog info + Booklet gp | 31 | Went Up by: 1,302 (241, 2,363) | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Physical activity (mean steps/day) 6m | SHED IT group | 34 | Went Up by: 938 (−90, 1,966) | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Energy intake (kJ/day) 3m | Prog info + Booklet gp | 31 | Went down by: −2,068 (−3,089, −1,047) KJ/DAY | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Energy intake (kJ/day) 3m | SHED IT group | 34 | Went down by: −3,195 (−4,159, −2,230) KJ/DAY | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Energy intake (kJ/day) 6m | Prog info + Booklet gp | 31 | Went down by: −1,881 (−3,087, −676) KJ/DAY | | | | | | All differences statistically significant
Morgan, 2009^8^ Obesity | Energy intake (kJ/day) 6m | SHED IT group | 34 | Went down by: −3,642 (−4,764, −2,521) KJ/DAY | | | | | | All differences statistically significant
Taylor, 1991^9^ Obesity | Weight Loss (Post-treatment 12w – Pre-treatment) | Computer Assisted Therapy (fu 12 wks) | 28 | M 3.1 SD 2.2 (Loss to fu 4, therefore 24 subjects analyzed)
Taylor, 1991^9^ Obesity | Weight Loss (Post-treatment 12w – Pre-treatment) | 1200 calorie diet (Frozen Food) followed by CAT (fu 12 wks) | 27 | M = 5.3 SD 2.2 (Loss to fu 1, therefore 27 subject analyzed)
Taylor, 1991^9^ Obesity | Weight Loss (F/u @ 6m – Pre-treatment) | Computer Assisted Therapy | 21 | M 0.9 SD 3.6
Taylor, 1991^9^ Obesity | Weight Loss (F/u @ 6m – Pre-treatment) | 1200 calorie diet (Frozen Food) followed by CAT | 25 | M 3.8 SD 2.7
Williamson, 2006^10^ | Body weight (kg) | Control | 50 | | | | | 24 month: mean A: 6.3 P: 0.06 SD A: 1.6 P: 0.89
Williamson, 2006^10^ | Body weight (kg) | Interactive nutrition education program and Internet counseling behavioral therapy for the intervention group | 47 | Mean, A:93.3 P:101 SD, A: 22.5 P: 18.4 | | | | 24 month: mean, A: 4.4 P: 1.1 SD, A: 1.7 P: 0.91
Williamson, 2006^10^ | Body composition | Control | 50 | BMI | 6 month | 12 month | 18 month | 24 month mean, A: 1.2 P: 0.04 SD A: .65 P: .34
Williamson, 2006^10^ | Body composition | Interactive bNutrition education program and internet counseling behavioral therapy for the intervention group | 47 | Mean, A:36.4 P:38.4 SD, A: 7.9 P:7.2 | 6 month | 12 month | 18 month | 24 month mean, A: 0.73 P: 0.55 SD, A: .66, P: 0.34
Williamson, 2006^10^ | Weight loss behavior (body fat %) | Control | 50 | | 6 month | 12 month | 18 month | 24 month mean, A:0.84 P:0.51 SD, A:0.72 P:0.46
Williamson, 2006^10^ | Weight loss behavior (body fat %) | Interactive bNutrition education program and internet counseling behavioral therapy for the intervention group | 47 | Mean, A: 45.9 P: 48.4 SD, A: 7.5 P: 6.3 | 6 month | 12 month | 18 month | 24 month mean, A: −0.08 P:0.36 SD, A:0.71 P:0.46
Williamson, 2006^10^ | BMI (BMI percentile) | Control | 50 | | 6 month | 12 month | 18 month | 24 month mean, A: −0.001 SD, A: 0.003
Williamson, 2006^10^ | BMI (BMI percentile) | Interactive bNutrition education program and internet counseling behavioral therapy for the intervention group | 47 | | 6 month | 12 month | 18 month mean, A: −0.004 SD, A: 0.003 | 24 month
Womble, 2004^11^ | Weight change percent (%) | Control | 16 | | 16weeks mean, 3.6 SD, 4 | | | 52 weeks: mean, 4 SD, 5.1
Womble, 2004^11^ | Weight change percent (%) | ediets.com | 15 | | 16weeks mean, 0.9 SD, 3.2 | | | 52 weeks: mean, 1.1 SD, 4
Womble, 2004^11^ | Weight change (kg) | Control | 16 | | 16weeks mean, 3 SD, 3.1 | | | 52 weeks mean, 3.3 SD, 4.1
Womble, 2004^11^ | Weight change (kg) | ediets.com | 15 | | 16weeks mean, 0.7 SD, 2.7 | | | 52 weeks mean, 0.8 SD, 3.6

BMI = body mass index, BL = baseline, g = gram, kg = kilogram, SD = standard deviation, cm = centimeter, kg/m2 = Kilograms per square meter, kcal/day = kilocalories per day, A = Adolescents, P = parents

Reference List

1 Booth AO, Nowson CA, Matters H. Evaluation of an interactive, Internet-based weight loss program: a pilot study. Health Educ Res 2008; 23(3):371–81.

2 Burnett KF, Taylor CB, Agras WS. Ambulatory computer-assisted therapy for obesity: A new frontier for behavior therapy. 1985; 53(5):698–703.

3 Cussler EC, Teixeira PJ, Going SB et al. Maintenance of weight loss in overweight middle-aged women through the Internet. Obesity (Silver Spring) 2008; 16(5):1052–60.

4 Frenn M, Malin S, Brown RL et al. Changing the tide: An Internet/video exercise and low-fat diet intervention with middle-school students. 2005; 18(1):13–21.

5 Hunter CM, Peterson AL, Alvarez LM et al. Weight management using the internet a randomized controlled trial. Am J Prev Med 2008; 34(2):119–26.

6 Kroeze W, Oenema A, Campbell M, Brug J. The efficacy of Web-based and print-delivered computer-tailored interventions to reduce fat intake: results of a randomized, controlled trial. J Nutr Educ Behav 2008; 40(4):226–36.

7 McConnon A, Kirk SF, Cockroft JE et al. The Internet for weight control in an obese sample: results of a randomised controlled trial. BMC Health Serv Res 2007; 7:206.

8 Morgan PJ, Lubans DR, Collins CE, Warren JM, Callister R. The SHED-IT Randomized Controlled Trial: Evaluation of an Internet-based Weight-loss Program for Men. Obesity (Silver Spring) 2009.

9 Taylor CB, Agras WS, Losch M, Plante TG, Burnett K. Improving the effectiveness of computer-assisted weight loss. 1991; 22(2):229–36.

10 Williamson DA, Walden HM, White MA et al. Two-year internet-based randomized controlled trial for weight loss in African-American girls. Obesity (Silver Spring) 2006; 14(7):1231–43.

11 Womble LG, Wadden TA, McGuckin BG, Sargent SL, Rothman RA, Krauthamer-Ewing ES. A randomized controlled trial of a commercial internet weight loss program. Obes Res 2004; 12(6):1011–8.

Evidence Table 20

Description of RCTs addressing the impact of CHI applications on intermediate outcomes in diabetes (KQ1b)

Author, year | Consumer under study | CHI Application type | Location | Year data collected/duration of intervention | Inclusion criteria | Exclusion criteria | Control | Intervention | Jadad score
Diabetes mellitus
Glasgow, 2003^1^ | Individuals interested in their own health care | Personal monitoring device | NS | NS | Type 2 diabetes for more than 1 year, Planning to stay in area for one year, Meet Wellborn criteria for type 2 diabetes | | Basic information | Tailored self-management, Peer support | 0.5
Homko, 2007^2^ | Individuals interested in their own health care | Interactive consumer website | Home/residence | Duration, Sep 2004 to May 2006 | 18–45 yr, documented GDM on 3-h oral glucose tolerance test, using the criteria of Carpenter and Coustan, 33 weeks gestation or less | Prior history of glucose intolerance outside of pregnancy, multiple gestations | Usual care, paper logbooks | Telemedicine (website to document glucose levels and to communicate with health-care team) | 1.5
McKay, 2001^3^ | Individuals interested in their own health care | Interactive consumer website | Home/residence | NS | ≥ 40 or > 39 yr, Type 2 diabetes, physical activity level below the current minimum recommendation | Contraindication to moderate physical activity as assessed by the Physical Activity Readiness Questionnaire | Internet information only | Internet Active Lives Intervention | 2.5
Richardson, 2007 4 Diabetes | Type 2 diabetics | Pedometer hooked onto Interactive computer based feedback mechanism | Home/res | NS | 18 y/o Type 2 DM, email users w/Window XP/2000 and self reported moderate PA less than 150 min/week. English speaking. Interested in starting a walking program (cleared by a physician) | Pregnant women and folks who have used pedometer in last 30 days | Employing lifestyle goals for overall steps recorded from the pedometer | Employing structured goals that emphasize PA using computerized feedback mechanisms
Wangberg, 2006^5^ | Individuals interested in their own health care | Interactive consumer website | NS | NS | 17–67 yr, Type I or II diabetes, Access to the internet | | Low self-efficacy | | 2
Wise, 1986 6 Diabetes | Diabetic individuals both NIDDM and IDDM | Interactive computerized machine | Home /Res | Ns | Diabetics attending Charing Cross hospitaland having DM > 2 yrs | None specified | 3 controls Used: a. No intervention (used for Glucose control assessment) No KAP b. Just the assessment of the KAP c. Take-away corrective feedback | Interactive computerized machine
Diabetes, heart disease or chronic lung disease
Lorig, 2006^7^ | Individuals interested in their own health care | Interactive consumer website | NS | NS | >18 yr, Heart disease or chronic lung disease or Type 2 diabetes, Access to a computer with Internet and email capabilities, Agreed to 1–2 h/week of log on time spread over at least 3 sessions/wk for 6 wk, Able to complete the online questionnaire | No cancer treatment in past year, Participated in the small-group Chronic Disease Self-Management Program | Usual care | Treatment | 1.5

h = hours, NS = not specified, yr = year, GDM = Gestational Diabetes Mellitus, wk = week

Reference List

1 Glasgow RE, Boles SM, McKay HG, Feil EG, Barrera M Jr. The D-Net diabetes self-management program: long-term implementation, outcomes, and generalization results. Prev Med 2003; 36(4):410–9.

2 Homko CJ, Santamore WP, Whiteman V et al. Use of an internet-based telemedicine system to manage underserved women with gestational diabetes mellitus. Diabetes Technol Ther 2007; 9(3):297–306.

3 McKay HG, King D, Eakin EG, Seeley JR, Glasgow RE. The diabetes network internet-based physical activity intervention: a randomized pilot study. Diabetes Care 2001; 24(8):1328–34.

4 Richardson CR, Mehari KS, McIntyre LG et al. A randomized trial comparing structured and lifestyle goals in an internet-mediated walking program for people with type 2 diabetes. Int J Behav Nutr Phys Act 2007; 4:59.

5 Wangberg SC. An Internet-based diabetes self-care intervention tailored to self-efficacy. Health Educ Res 2008; 23(1):170–9.

6 Wise PH, Dowlatshahi DC, Farrant S. Effect of computer-based learning on diabetes knowledge and control. 1986; 9(5):504–8.

7 Lorig KR, Ritter PL, Laurent DD, Plant K. Internet-based chronic disease self-management: a randomized trial. Med Care 2006; 44(11):964–71.

Evidence Table 21

Description of consumer characteristics in studies addressing the impact of CHI applications on intermediate outcomes in diabetes (KQ1b)

Author, year | Control Interventions | Age | Race, n (%) | Income | Education, n(%) | SES | Gender n (%) | Marital Status | Other outcomes
Diabetes mellitus
Glasgow, 2003^1^ | Basic information | Baseline characteristics not reported
Glasgow, 2003^1^ | Tailored self-management intervention | Baseline characteristics not reported
Homko, 2007^2^ | Usual care, Paper logbooks | Mean, 29.2 SD, 6.7 | White non-Hispanic, 6(24) Black non-Hispanic, 12(48) Latino/Hispanic, 4(16) API, 3(12) | USD <15,000, 10(40) 15,000-$34,999, 3(12) 35,000-$54,999, 3(12) >55,000, 3(12) missing, 6(24) | < 8 yr, 2(8) 8–12 yr, 12(48) 12–16 yr, 10(40) | NR | | | BMI: mean, 32.5 SD, 7.1 Gravidity: mean, 2.9 SD, 2.3 Glucose challenge (mg/dl): mean, 179.1 SD, 45.2 GA at diagnosis (weeks): mean, 27.7 SD, 3.8
Homko, 2007^2^ | Telemedicine (website to document glucose levels and to communicate with health-care team) | Mean, 29.8 SD, 6.6 | White non-Hispanic, 8(25) Black non-Hispanic, 14(44) Latino/Hispanic, 7(22) API, 3(9) | USD <15,000, 8(25) 15,000-$34,999, 8(25) 35,000-$54,999, 3(9) >55,000, 6(19) missing, 7(22) | < 8 yr, 4(12.5), 8–12 yr, 12(37.5) 12–16 yr,15(47) | NR | | | BMI : mean, 33.4 SD, 8.6 gravidity: mean, 3 SD, 1.8 glucose challenge (mg/dl): mean, 159.5 SD, 46.3 GA at diagnosis (weeks): mean, 27.5 SD, 4.2
McKay, 2001^3^ | Internet information only | Mean, 52.3 | White non-Hispanic, (82) | NS | 12–16 yr, (50 ) | NR | | | Treatment: Taking Insulin: (22) Diagnosed with diabetes for over one or more co morbid chronic disease: (75)
McKay, 2001^3^ | Internet-based physical activity intervention | NS | NS | NS | NS | NR | | | NS
Richardson, 2007 4 Diabetes | Employing lifestyle goals for overall steps recorded from the pedometer | 52 +- 12 | W (76) B (18) O (6) | <30K-18 30–70K-18 >70K-65 (percent) | HS DIP/GED: 6 Some Coll:47 Coll Degree: 18 Grad Degree: 29 | NS | M (29)
Richardson, 2007 4 Diabetes | Employing structured goals that emphasize PA using computerized feedback mechanisms | 53 +-9 | W (77) B (8) O (15) | <30K-8 30–70K-31 >70K-62 (percent) | HS DIP/GED: 8 Some Coll:15 Coll Degree:46 Grad Degree:31 | NS | M (38)
Wangberg, 2006^5^ | Low self-efficacy | Mean, 37.3 range, 33.2–41.4 | NS | NS | 8–12 yr, (11) | NR | F, (63) | | Type I Diabetes: (72) Insulin use: (78) HbA1C: (7.7)
Wangberg, 2006^5^ | High self-efficacy | Mean, 42.9 range, 38.0–47.9 | NS | NS | 8–12 yr, (8) | NR | F, (50) | | Type I Diabetes: (50) Insulin use: (71) HbA1C: (7.2)
Wise, 1986 6 Diabetes | IDDM | 42 +/− 16 | NS | NS | NS | | Sex ratio varied from 0.42 to 0.60. The study does not specify any other detail
Wise, 1986 6 Diabetes | Control Group (AGE +/− SE)
Wise, 1986 6 Diabetes | Assessment on KAP | 44 +/− 17
Wise, 1986 6 Diabetes | KAP –Feedback – KAP | 45 +/− 16
Wise, 1986 6 Diabetes | KAP –Interactive computer –KAP | 41 +/− 18
Wise, 1986 6 Diabetes | NIDDM | 55 +/− 21 | NS | NS | NS | | Sex ratio varied from 0.42 to 0.60. The study does not specify any other detail
Wise, 1986 6 Diabetes | Control Group (AGE +/− SE)
Wise, 1986 6 Diabetes | Assessment on KAP | 57 +/− 23
Wise, 1986 6 Diabetes | KAP –Feedback – KAP | 58 +/− 17
Wise, 1986 6 Diabetes | KAP –Interactive computer –KAP | 56 +/− 16
Diabetes, heart disease or chronic lung disease
Lorig , 2006^7^ | Usual care | Mean, 57.6 SD, 11.3 | White non-Hispanic, (88.7) | NS | NS | NR | F, (71.6)
Lorig , 2006^7^ | Online intervention | Mean, 57.4 SD, 10.5 | White non-Hispanic, (87.3) | NS | NS | NR | F, (71.2)

F = female, M = male, NS = Not specified, NR = Not reported, SES = Socio economic status, API = Asian/Pacific Islander, mg/dl = milligrams/deciliter, HbA1c = hemoglobin A1c, yr = year, USD = united states dollar

Reference List

1 Glasgow RE, Boles SM, McKay HG, Feil EG, Barrera M Jr. The D-Net diabetes self-management program: long-term implementation, outcomes, and generalization results. Prev Med 2003; 36(4):410–9.

2 Homko CJ, Santamore WP, Whiteman V et al. Use of an internet-based telemedicine system to manage underserved women with gestational diabetes mellitus. Diabetes Technol Ther 2007; 9(3):297–306.

3 McKay HG, King D, Eakin EG, Seeley JR, Glasgow RE. The diabetes network internet-based physical activity intervention: a randomized pilot study. Diabetes Care 2001; 24(8):1328–34.

4 Richardson CR, Mehari KS, McIntyre LG et al. A randomized trial comparing structured and lifestyle goals in an internet-mediated walking program for people with type 2 diabetes. Int J Behav Nutr Phys Act 2007; 4:59.

5 Wangberg SC. An Internet-based diabetes self-care intervention tailored to self-efficacy. Health Educ Res 2008; 23(1):170–9.

6 Wise PH, Dowlatshahi DC, Farrant S. Effect of computer-based learning on diabetes knowledge and control. 1986; 9(5):504–8.

7 Lorig KR, Ritter PL, Laurent DD, Plant K. Internet-based chronic disease self-management: a randomized trial. Med Care 2006; 44(11):964–71.

Evidence Table 22

Outcomes in studies addressing the impact of CHI applications on intermediate outcomes in diabetes

Author,year | Outcomes | Control Intervention | n | Measure at BL | Measure at final time point | ratios at time points | Significance
Diabetes mellitus
Glasgow, 2003^1^ | Kristal total (Dietary behavior) | Control | | Mean, 2.22 SD, 0.45 | 10 months: mean, 2.03 SD, 0.38
Glasgow, 2003^1^ | Kristal total (Dietary behavior) | Tailored self-management intervention | | Mean, 2.19 SD, 0.46 | 10 months: mean, 1.93 SD, 0.38
Glasgow, 2003^1^ | Estimated grams of daily fat (grams) | Control | | Mean, 44.4 SD, 33.8 | 10 months mean, 29.8 SD, 14.3
Glasgow, 2003^1^ | Estimated grams of daily fat (grams) | Tailored self-management | | Mean, 40.8 SD, 23.8 | 10 months mean, 27.9 SD, 14.3
Glasgow, 2003^1^ | Minutes activity per day (minutes/day) | Control | | Mean, 26.8 SD, 20.4 | 10 months mean, 32.1 SD, 22.9
Glasgow, 2003^1^ | Minutes activity per day (minutes/day) | Tailored self-management | | Mean, 33.4 SD, 25.4 | 10 months mean, 30.9 SD, 23
Glasgow, 2003^1^ | Minutes activity per day | Control | | Mean, 66.68 SD, 20.66 | 10 months mean, 79.97 SD, 14.81
Glasgow, 2003^1^ | Minutes activity per day | Tailored self-management | | Mean, 63.32 SD, 19.69 | 10 months mean, 78.4 SD, 14.81
Glasgow, 2003^1^ | Guidelines met (% guidelines met) | Control | | Mean, 7.43 SD, 1.71 | 10 months mean, 7.67 SD, 1.1
Glasgow, 2003^1^ | Guidelines met (% guidelines met) | Tailored self-management | | mean, 1.53 | 10 months mean, 7.42 SD, 1.1
Glasgow, 2003^1^ | Hemoglobin A1C | Control | | Mean, 5.18 SD, 1.44 | 10 months: mean, 5.02 SD, 1.17
Glasgow, 2003^1^ | Hemoglobin A1C | Tailored self-management | | Mean, 5.7 SD, 1.89 | 10 months: mean, 5.13 SD, 1.16
Glasgow, 2003^1^ | Lipid ratio | Control | | Mean, 17.9 SD, 10.56 | 10 months mean, 12.93 SD, 9.11
Glasgow, 2003^1^ | Lipid ratio | Tailored self-management | | Mean, 18 SD, 10.02 | 10 months mean, 13.72 SD, 9.12
Glasgow, 2003^1^ | CES-D total | Control | | Mean, 4.14 SD, 1.32 | 10 months mean, 4.96 SD, 1.12
Glasgow, 2003^1^ | CES-D total | Tailored self-management | | Mean, 4.14 SD, 1.2 | 10 months mean, 4.97 SD, 1.12
Homko, 2007^2^ | Self-efficacy (DES) | Control | 25 | Score on DES | 37 weeks gestation: mean, 4 SD, 0.5 | | NS
Homko, 2007^2^ | Self-efficacy (DES) | Telemedicine | 32 | Score on DES | 37 weeks gestation: mean, 4.4 SD, 0.5 | | NS
Homko, 2007^2^ | System use (# of sets of information sent on telemedicine system) | Control | 25 | Frequency of monitoring (sets of data reported) | 37 weeks gestation mean, 73.7 SD, 56.7 | | NS
Homko, 2007^2^ | System use (# of sets of information sent on telemedicine system) | Telemedicine | 28 | | 37 weeks gestation mean, 94.8 SD, 60 | | NS
Homko, 2007^2^ | FBS | Control | 25 | FBS (mg/dl) | 37 weeks gestation mean, 88.6 SD, 9.5 | | NS
Homko, 2007^2^ | FBS | Telemedicine | 32 | | 37 weeks gestation mean, 90.8 SD, 11.8 | | NS
Homko, 2007^2^ | A1c at time of delivery | Control | 25 | A1c at delivery (%) | 37 weeks gestation mean, 6.2 SD, 2.2 | | NS
Homko, 2007^2^ | A1c at time of delivery | Telemedicine | 32 | | 37 weeks gestation mean, 6.1 SD, 0.8 | | NS
McKay, 2001^3^ | Moderate-to-vigorous exercise Unadjusted (minutes/day) | Control | 33 | Mean, 7.3 SD, 6.2 | 8 weeks mean, 18 SD, 17.3
McKay, 2001^3^ | Moderate-to-vigorous exercise Unadjusted (minutes/day) | Internet-based physical activity intervention | 35 | Mean, 5.6 SD, 6.2 | 8 weeks mean, 17.6 SD, 15.3
McKay, 2001^3^ | Walking Unadjusted (minutes/day) | Control | 33 | Mean, 8.4 SD, 8.4 | 8 weeks mean, 16.8 SD, 22.8
McKay, 2001^3^ | Walking Unadjusted (minutes/day) | Internet-based physical activity intervention | 35 | Mean, 6.4 SD, 6.2 | 8 weeks mean, 12.5 SD, 9.5
McKay, 2001^3^ | Depressive symptoms | Control | 33 | Mean, 17.6 SD, 10.4 | 8 weeks mean, 19.9 SD, 14.2
McKay, 2001^3^ | Depressive symptoms | Internet-based physical activity intervention | 35 | Mean, 16.9 SD, 11.6 | 8 weeks mean, 14.9 SD, 12.5
Richardson, 2007 4 Diabetes | Total Step | Employing lifestyle goals for overall steps recorded from the pedometer | 17 | 4,157 ± 1,737 stps | 6,279 ± 3,306 | Diff: 2,122 ± 3,179 | Ns
Richardson, 2007 4 Diabetes | | Employing structured goals that emphasize PA using computerized feedback mechanisms | 13 | 5,171 ± 1,769 | 6,868 ± 3,751 | Diff: 1,697 ± 3,564 | NS
Richardson, 2007 4 Diabetes | Bout Steps | Employing lifestyle goals for overall steps recorded from the pedometer | 17 | 286 ± 599 | 2,070 ± 2,814 | 1,783 ± 2,741 | S
Richardson, 2007 4 Diabetes | | Employing lifestyle goals for overall steps recorded from the pedometer | 13 | 516 ± 801 (NS from above) | 2,616 ± 2,706 (NS diff from above) | 2,101 ± 2,815 (NS Diff from above) | S
Richardson, 2007 4 Diabetes | Satisfaction | Employing lifestyle goals for overall steps recorded from the pedometer | 17 | | | 100%
Richardson, 2007 4 Diabetes | | Employing lifestyle goals for overall steps recorded from the pedometer | 13 | | | 62% | P =0.006
Richardson, 2007 4 Diabetes | Usefulness | Employing lifestyle goals for overall steps recorded from the pedometer | 17 | | | 71%
Richardson, 2007 4 Diabetes | | Employing lifestyle goals for overall steps recorded from the pedometer | 13 | | | 31% | P = 0.03
Richardson, 2007 4 Diabetes | Adherence (Likelihood of wearing a pedometer) | Employing lifestyle goals for overall steps recorded from the pedometer | 17 | | | (3)
Richardson, 2007 4 Diabetes | | Employing lifestyle goals for overall steps recorded from the pedometer | 13 | | | (15) | P < 0.001
Richardson, 2007 4 Diabetes | Adherence (Mean hours of wearing a pedometer) | Employing lifestyle goals for overall steps recorded from the pedometer | 17 | | 16.5h
Richardson, 2007 4 Diabetes | | Employing lifestyle goals for overall steps recorded from the pedometer | 13 | | 14.5h | | P = 0.038
Wangberg, 2006^5^ | Summary of Diabetes Self Care Activities | Low self-efficacy | 15 | Mean, 29.47 SD, 9.49 | 1 month - analyzed: mean, 30.60 SD, 8.92
Wangberg, 2006^5^ | Summary of Diabetes Self Care Activities | High self-efficacy | 14 | Mean, 27.64 SD, 8.55 | 1 month - analyzed: mean, 32.07 SD, 7.5
Wangberg, 2006^5^ | Perceived competence scale | Low self-efficacy | 15 | Mean, 52.20 SD, 13.19 | 1 month - analyzed mean, 49.73 SD, 14.18
Wangberg, 2006^5^ | Perceived competence scale | High low self-efficacy | 14 | Mean, 52.07 SD, 10.66 | 1 month - analyzed mean, 49.93 SD, 10.83
Wise, 1986 6 Diabetes | IDDM Patients
Wise, 1986 6 Diabetes | Knowledge Index (KAP Questionnaire) 4—6mo | Assessment of KAP only | 24 | Knowledge Score: 79 SE 2 | 82 SE 2 | | Ns
Wise, 1986 6 Diabetes | | Assessment + Feedback | 22 | 78 SE 2 | 83 SE 3 | | significant
Wise, 1986 6 Diabetes | | Assessment + Interactive computer | 20 | 77 SE 2 | 83 SE 2 | | Significant
Wise, 1986 6 Diabetes | NIDDM Patients
Wise, 1986 6 Diabetes | Knowledge Index (KAP Questionnaire) 4—6mo | Assessment of KAP only | 22 | Knowledge UNS | UNS | | Ns
Wise, 1986 6 Diabetes | | Assessment + Feedback | 24 | 64 SE 2 | 73 SE 2 | | significant
Wise, 1986 6 Diabetes | | Assessment + Interactive computer | 21 | 60 SE 3 | 70 SE 2 | | Significant
Wise, 1986 6 Diabetes | IDDM Patients
Wise, 1986 6 Diabetes | Knowledge Index (KAP Questionnaire) 4—6mo | Control | 20 | HBA1c: 8.9% | 8.8% | | NS
Wise, 1986 6 Diabetes | | Assessment of KAP only | 24 | 9.1 SE 0.2 | 8.4 SE 0.1 | | Significant
Wise, 1986 6 Diabetes | | Assessment + Feedback | 22 | 9.3 SE 0.5 | 8.1 SE 0.4 | | significant
Wise, 1986 6 Diabetes | | Assessment + Interactive computer | 20 | 9.3 SE 0.2 | 8.6 SE 0.3 | | Significant
Wise, 1986 6 Diabetes | NIDDM Patients
Wise, 1986 6 Diabetes | Knowledge Index (KAP Questionnaire) 4—6mo | Control | 21 | HBA1c: 8.7% | 8.5% | | NS
Wise, 1986 6 Diabetes | | Assessment of KAP only | 22 | 9.6 SE 0.4 | 8.8 SE 0.3 | | Significant
Wise, 1986 6 Diabetes | | Assessment + Feedback | 24 | 9.2 SE 0.4 | 7.9 SE 0.4 | | significant
Wise, 1986 6 Diabetes | | Assessment + Interactive computer | 21 | 8.7 SE 0.7 | 7.9 SE 0.6 | | Significant
Diabetes, heart disease or chronic lung disease
Lorig, 2006^7^ | Change in health distress (0–5) | Control | 426 | CHANGE in score on Health Distress Scale | 12 months: mean, −0.193 SD, 1.07 | | 0.–13 (ANCOVA) 0.025 (repeated measures)
Lorig, 2006^7^ | Change in health distress (0–5) | Online intervention | 354 | CHANGE in score on Health Distress Scale | 12 months: mean, −0.377 SD, 1.11 | | 0.–13 (ANCOVA) 0.025 (repeated measures)
Lorig, 2006^7^ | Change in self reported global health(0–5) | Control | 426 | 0–5 scale | 12 months mean, −0.068 SD, 0.645 | | 0.340 (logistic) 0.514 (repeated measures)
Lorig, 2006^7^ | Change in self reported global health(0–5) | Online intervention | 354 | | 12 months mean, −0.102 SD, 0.768 | | 0.340 (logistic) 0.514 (repeated measures)
Lorig, 2006^7^ | Change in illness intrusiveness | Control | 426 | 1–7scale | 12 months mean, −0.064 SD, 0.926 | | 0.704 (ANCOVA), 0.061 (repeated measures)
Lorig, 2006^7^ | Change in illness intrusiveness | Online intervention | 354 | | 12 months mean, −0.150 SD, 1.023 | | 0.704 (ANCOVA), 0.061 (repeated measures)
Lorig, 2006^7^ | Change in disability | Control | 426 | 0–3 Scale | 12 months mean, −0.142 SD, 0.32 | | BL, 0.051 (ANCOVA) 0.335 repeated measures
Lorig, 2006^7^ | Change in disability | Online intervention | 354 | | 12 months mean, −0.166 SD, 0.345 | | BL, 0.051 (ANCOVA) 0.335 repeated measures
Lorig, 2006^7^ | Change in fatigue | Control | 426 | 0–10scale | 12 months: mean, −0.358 SD, 2.09
Lorig, 2006^7^ | Change in fatigue | Online intervention | 354 | | 12 months: mean, −0.720 SD, 2.14
Lorig, 2006^7^ | Change in pain | Control | 426 | 0–10 scale | 12 months mean, −0.047 SD, 2.46
Lorig, 2006^7^ | Change in pain | Online intervention | 354 | | 12 months mean, −0.367 SD, 2.72
Lorig, 2006^7^ | Change in shortness of breath | Control | 426 | 0–10 scale | 12 months mean, −0.216 SD, 2.4
Lorig, 2006^7^ | Change in shortness of breath | Online intervention | 354 | | 12 months mean, −0.537 SD, 2.41
Lorig, 2006^7^ | Change in self-efficacy | Control | 426 | 1–10 Scale | 12 months: mean, 0.200 SD, 1.82
Lorig, 2006^7^ | Change in self-efficacy | Online intervention | 354 | 1–10 Scale | 12 months: mean, 0.406 SD, 1.98

FBS = fasting blood sugar, DES = Diabetes Empowerment Scale, BL = baseline, NS = not significant, mg/dl = milligrams/deciliter

Reference List

1 Glasgow RE, Boles SM, McKay HG, Feil EG, Barrera M Jr. The D-Net diabetes self-management program: long-term implementation, outcomes, and generalization results. Prev Med 2003; 36(4):410–9.

2 Homko CJ, Santamore WP, Whiteman V et al. Use of an internet-based telemedicine system to manage underserved women with gestational diabetes mellitus. Diabetes Technol Ther 2007; 9(3):297–306.

3 McKay HG, King D, Eakin EG, Seeley JR, Glasgow RE. The diabetes network internet-based physical activity intervention: a randomized pilot study. Diabetes Care 2001; 24(8):1328–34.

4 Richardson CR, Mehari KS, McIntyre LG et al. A randomized trial comparing structured and lifestyle goals in an internet-mediated walking program for people with type 2 diabetes. Int J Behav Nutr Phys Act 2007; 4:59.

5 Wangberg SC. An Internet-based diabetes self-care intervention tailored to self-efficacy. Health Educ Res 2008; 23(1):170–9.

6 Wise PH, Dowlatshahi DC, Farrant S. Effect of computer-based learning on diabetes knowledge and control. 1986; 9(5):504–8.

7 Lorig KR, Ritter PL, Laurent DD, Plant K. Internet-based chronic disease self-management: a randomized trial. Med Care 2006; 44(11):964–71.

Evidence table 23

Description of RCTs addressing the impact of CHI applications on intermediate outcomes in mental health

Author, year | Consumer under study | CHI Application type | Location | Year data collected/ duration of intervention | Inclusion criteria | Exclusion criteria | Control | Intervention | Jadad score
Depression/anxiety
Christensen, 2004^1^ | Individual interested in their own health care | Interactive consumer website | NS | NS | ≥18 yr, Internet access, 22 or higher on the Kessler psychological distress scale | >52 yr, receiving clinical care from either a psychologist or psychiatrist | Control | Mood GYM, Blue Pages | 2
Neil, 2009^2^ | Depressed/Anxious youth | Interactive consumer website | School – classroom / community | 2006–07 | Adolescents 13 – 17 yrs completing the YouthMood project | NS | Use of website (open access) in community | Use of website (open access) in classroom
Proudfoot, 2004^3^ | Individual interested in their own health care | Computerized cognitive behavioral therapy | Clinician office | NS | 18–75 yr, Depression, Anxiety and depression, Anxiety, Not currently receiving any form of psychological treatment or counseling, Score of 4 or more on the 12 item general health questionnaire, 12 or more on the computer version of the Clinical Interview Schedule-Revised | Active suicidal ideas, Diagnosis of psychosis or organic mental disorder, alcohol and/or drug dependence, Medication for anxiety and/or depression continuously for 6 months or more immediately prior to entry, Unable to attend 8 sessions at the surgery, Unable to read or write English | Treatment as usual | Computerized therapy | 3
Warmerdam,2008^4^ | Depressed / Anxious | Interactive Consumer website | Home / res | 08-09/06 – 01-02/07 | >18 yrs, Score of >=16 on CES-D, knew Dutch, internet and email access | CES-D scores greater than 32 | Wait-listed controls | Interactive computer tool based on Cog. Beh. Theory and Prob. Sol. Theory
Phobia
Schneider, 2005^5^ | Individual interested in their own health care | Web based tailored self help information | Home/ residence, Remote location: preferred site of patient | NS | Fulfill ICD-10 criteria for agoraphobia with/without panic disorder, social phobia or specific phobia, 4≥ for global phobia, Main goal negotiated and set with clinician, phobia for more than one year, Men: alcohol <21 units/week, Women: alcohol <14 units/week, No reading disorder hindering net use | Current psychotic illness, suicide plans, no severe depression, disabling cardiac or respiratory disease, On benzodiazepine or diazepam equivalent dose of >5 mg/day, began or changed dose or type of antidepressant within the last 4 weeks, Substance abuse, Failed past exposure therapy of >4 sessions | | Managing Anxiety application, Fear Fighter application | 1
Stress
Chiauzzi, 2008^6^ | | Interactive consumer website, | University | 2005 | ≥18 and ≤24 yr, college students, scoring above 14 on the | | A control website (CW) | MyStudentBody–Stress website, No treatment control (NTX) | 0
Hasson, 2005^7^ | Individual interested in their own health care | Personal monitoring device | NS | NS | Employment at a company insured by Alecta (occupational pension plan company) | those who quit employment prior to completion of study, “communication related problem” | Access to web-based tool | Web-based tool with control group components plus self-help with stress management exercises and chat | 2
Stress Management
Zetterqvist, 2003^8^ | For stress management for gen population | Interactive consumer web | Home / res | 04/2000 – 06-07/2000 | No specified inclusion or exclusion criteria unless the participant expressed a condition that would prevent him / her from completing the study | | Control | Interactive self help stress management program

NS = not specified, Yr = year

Reference List

1 Christensen H, Griffiths KM, Jorm AF. Delivering interventions for depression by using the internet: randomised controlled trial. BMJ 2004; 328(7434):265.

2 Neil AL, Batterham P, Christensen H, Bennett K, Griffiths KM. Predictors of adherence by adolescents to a cognitive behavior therapy website in school and community-based settings. J Med Internet Res 2009; 11(1):e6.

3 Proudfoot J, Ryden C, Everitt B et al. Clinical efficacy of computerised cognitive-behavioural therapy for anxiety and depression in primary care: randomised controlled trial. Br J Psychiatry 2004; 185:46–54.

4 Warmerdam L, van Straten A, Twisk J, Riper H, Cuijpers P. Internet-based treatment for adults with depressive symptoms: randomized controlled trial. J Med Internet Res 2008; 10(4):e44.

5 Schneider AJ, Mataix-Cols D, Marks IM, Bachofen M. Internet-guided self-help with or without exposure therapy for phobic and panic disorders. Psychother Psychosom 2005; 74(3):154–64.

6 Chiauzzi E, Brevard J, Thurn C, Decembrele S, Lord S. MyStudentBody-Stress: an online stress management intervention for college students. J Health Commun 2008; 13(6):555–72.

7 Hasson D, Anderberg UM, Theorell T, Arnetz BB. Psychophysiological effects of a web-based stress management system: a prospective, randomized controlled intervention study of IT and media workers. BMC Public Health 2005; 5:78.

8 Zetterqvist K, Maanmies J, Str+¦m L, Andersson G. Randomized controlled trial of internet-based stress management. 2003; 32(3):151–60.

Evidence Table 24

Description of consumer characteristics studies addressing the impact of CHI applications on intermediate outcomes in mental health

Author, year | Control Interventions | Age | Race, n(%) | Income | Education, n(%) | SES | Gender, n(%) | Marital Status, n(%) | Other
Depression/anxiety
Proudfoot, 2004^1^ | Usual care | Mean, 43.4 SD, 13.7 | Bangladeshi, 1(1) Black Caribbean, 4(4) Indian, 3(3) Pakistani, 1(1) White, 100(87) | | 0–10 yr, 17(14) 11–12 yr, 28(23) 13–15 yr, 30(25) >15 yr, 46(38) | | M, 32(25) F, 96(75) | Single, 33(26) Married, 54(43) Cohabiting, 11(9) Separated, 7(6) Divorced, 15(12) Widowed, 5(4) | Previous computer use No, 23(18) Yes, 103(82)
Proudfoot, 2004^1^ | Internet therapy | Mean, 43.6 SD, 14.3 | Black African, 1(1) Black Caribbean, 2(2) Black other, 3(2) White, 120(90) | | <5 yr, 1(1) 11–12 yr, 34(24) 13–15 yr, 31(22) >15 yr, 58(41) | | M, 40(27) F, 106(73) | Single, 35(25) Married, 60(43) Cohabiting, 16(11) Separated, 4(3) Divorced, 18(13) Widowed, 8(6)
Christensen, 2004^2^ | Control | Mean, 36.29 SD, 9.3 | | | Mean, 14.4 SD, 2.3 | | F, 124(70) M, 54(30) | Married Cohabiting, 100(56) Divorced/separated, 24(14) Never married, 53(36) | Kessler psychological distress scale, mean, 18 SD, 5.7 Center for Epidemiologic studies depression score, mean, 21.6 SD, 11.1
Christensen, 2004^2^ | Mood gym | Mean, 35.85 SD, 9.5 | | | Mean, 14.6 SD, 2.4 | | F, 136(75) M, 46(25) | Married/cohabiting, 98(54) Divorced/separated, 26(14) Never married, 57(31) | Kessler psychological distress scale, mean, 17.9 SD, 5 Center for Epidemiologic Studies depression scale, mean, 21.8 SD, 10.5
Christensen, 2004^2^ | Blue Pages | Mean, 37.25 SD, 9.4 | | | Mean, 15 SD, 2.4 | | F, 115(69) M, 50(31) | Married/cohabiting, 100(61) Divorced/separated, 24(15) Never Married, 53(30) | Kessler psychological distress scale, mean, 17.5 SD, 4.9 Center for Epidemiologic Studies depression scale, mean, 21.1 SD, 10.4
Neil, 2009^3^ | Use of website (open access) in community | 13 – 17 yrs | NS | | | | 5223/7207 F 72% | | (19) rural area (N 1396) (66) depressed (N 4734)
Neil, 2009^3^ | Use of website (open access) in classroom | 13 – 17 yrs | | | | | 597/1000 F (59.7) | | (19) from rural area (N 193) (29) depressed (N 287)
Warmerdam, 2008^4^ | Wait-listed controls (87) | 44.1 | NS | Paid Jobs w/: 49 (58.3) | Lower: 9 (10.3) Middle: 28 (32.2) Higher: 50 (57.5) | NR | 69 (79.3)
Warmerdam, 2008^4^ | Interactive computer tool based on Cog. Beh. Theory (88) | 45.7 | | 43 (52.4) | Lower: 9 (10.2) Middle: 26 (29.5) Higher: 53 (60.2) | | 61 (69.3)
Warmerdam, 2008^4^ | Interactive computer tool based on Prob. Sol. Theory (88) | 45.1 | | 43 (50.6) | Lower: 5 (5.7) Middle: 18 (20.5) Higher: 65 (73.9) | | 57 (64.8)
Phobia
Schneider, 2005^5^ | Control | NS | NS | NS | NS | NR | | | NS
Schneider, 2005^5^ | Computer aided cognitive behavior therapy with self-help exposure | NS | NS | NS | NS | NR | | | NS
Stress
Chiauzzi, 2008^6^ | A control website(CW), | Range, 18–24 | White non-Hispanic, 48 black non-Hispanic, 12 Latino/Hispanic, 9 API,(16) Other 7 | NS | Yr in School(n), First, 29 Second, 18 Third, 19 Fourth, 17 | NR | M, 40 F, 43
Chiauzzi, 2008^6^ | MyStudent Body–Stress website | Range, 18–24 | White non-Hispanic, 44 Black non-Hispanic, 13 Latino/Hispanic, 5 API, 14 Other, 7 | NS | Yr in School(n), First, 30 Second, 16 Third, 19 Fourth, 13 | NR | M, 34 F, 44
Chiauzzi, 2008^6^ | NTX | Range, 18–24 | White non-Hispanic, 50 Black non-Hispanic, 7 Latino/Hispanic, 8 API, 13 Other, 8 | NS | Yr in school (n), First, 23 Second, 19 Third, 12 Fourth, 24 | NR | M, 42 F, 36
Hasson, 2005^7^ | Access to web-based tool including monitoring tool for stress and health; diary connected to monitoring tool, and scientific info on stress and health | NS | NS | USD <25,000, 39(22) 25,000–40,000, 106(61) >40,000, 27(16) | 8–12 yr, 89(51) 12–16yr, 83(48) | NR | M, 112(64) F, 62(36) | Married, 134(77) Single, 38(22)
Hasson, 2005^7^ | | NS | NS | USD <25,000, 24(18) 25,000–40,000, 76(59) >40,000, 27(21) | 8–12yr, 54(42) 12–16yr, 73(57) | NR | M, 75(58) F, 54(42) | Married, 102(79) Single, 25(19)
Stress Management
Zetterqvist, 2003^8^ | Control Group | 38.7 (26—60) | NS | Work hours per week: 36.3 (0—60) | Student: 5 (12) Work: 33 (83) Unemployed: 2 (5) | NS | M: 14/40 (35%) | | Civil Standing: Single: 14 (35) Living with partner: 9 (23) Married: 17 (43) | No. of children: Mean: 0.98 (0—4)
Zetterqvist, 2003^8^ | Self Help for stress management via internet | 40.0 (24—56) | | Mean: 29.6 (0—60) | Student: 5 (22) Work: 15 (65) Unemployed:3 (13) | | M: 10/23 (43%) | | Single: 8 (35) Living with partner: 6 (26) Married: 9 (39)

NR = Not reported, M = male, F = female, AIAN = American Indian/Alaska Native, API = American/Pacific Islander, SD = standard deviation, SES= Socioeconomic Status, USD = United States Dollar

Reference List

1 Proudfoot J, Ryden C, Everitt B et al. Clinical efficacy of computerised cognitive-behavioural therapy for anxiety and depression in primary care: randomised controlled trial. Br J Psychiatry 2004; 185:46–54.

2 Christensen H, Griffiths KM, Jorm AF. Delivering interventions for depression by using the internet: randomised controlled trial. BMJ 2004; 328(7434):265.

3 Neil AL, Batterham P, Christensen H, Bennett K, Griffiths KM. Predictors of adherence by adolescents to a cognitive behavior therapy website in school and community-based settings. J Med Internet Res 2009; 11(1):e6.

4 Warmerdam L, van Straten A, Twisk J, Riper H, Cuijpers P. Internet-based treatment for adults with depressive symptoms: randomized controlled trial. J Med Internet Res 2008; 10(4):e44.

5 Schneider AJ, Mataix-Cols D, Marks IM, Bachofen M. Internet-guided self-help with or without exposure therapy for phobic and panic disorders. Psychother Psychosom 2005; 74(3):154–64.

6 Chiauzzi E, Brevard J, Thurn C, Decembrele S, Lord S. MyStudentBody-Stress: an online stress management intervention for college students. J Health Commun 2008; 13(6):555–72.

7 Hasson D, Anderberg UM, Theorell T, Arnetz BB. Psychophysiological effects of a web-based stress management system: a prospective, randomized controlled intervention study of IT and media workers. BMC Public Health 2005; 5:78.

8 Zetterqvist K, Maanmies J, Str+¦m L, Andersson G. Randomized controlled trial of internet-based stress management. 2003; 32(3):151–60.

Evidence Table 25

Outcomes in studies addressing the impact of CHI applications on intermediate outcomes in mental health

Author, year | Outcomes | Control Intervention | n | Measure at BL | Measure at time point 2 | Measure at time point 3 | Measure at time point 4 | Measure at final time point | Ratios at time points | Significances
Depression/anxiety
Proudfoot, 2004^1^ | Depression (BDI) | Control | 109 | BDI | | | | 6 Month: mean,16.2 SD, 10.1 | | 0.0006
Proudfoot, 2004^1^ | Depression (BDI) | Computerized Therapy | 112 | BDI | | | | 6 Month: mean, 11.6 SD, 9.6 | | 0.0006
Proudfoot, 2004^1^ | Anxiety (BAI) | Control | 110 | BAI | | | | 6 Month mean, 12.8 SD, 9.1 | | 0.06
Proudfoot, 2004^1^ | Anxiety (BAI) | Computerized Therapy | 115 | BAI | | | | 6 Month mean, 10.6 SD, 8.4 | | 0.06
Proudfoot, 2004^1^ | Work and Social Adjustment scale | Control | 110 | | | | | 6 Month mean, 13.4 SD, 8.6
Proudfoot, 2004^1^ | Work and Social Adjustment scale | computerized therapy | 115 | | | | | 6 Month mean, 10 SD, 7.8
Proudfoot, 2004^1^ | ASQ,CoNeg | Control | 106 | | | | | 6 Month mean, 84.1 SD, 13.6
Proudfoot, 2004^1^ | ASQ,CoNeg | Computerized therapy | 106 | | | | | 6 Month mean, 73.7 SD, 15.3
Proudfoot, 2004^1^ | ASQ,CoPos | Control | 106 | | | | | 6 Month: mean, 82.8 SD, 12.5
Proudfoot, 2004^1^ | ASQ,CoPos | Computerized therapy | 108 | | | | | 6 Month: mean, 87.6 SD, 13.5
Neil, 2009^2^ | Depression score (Pre-test) | Use of website (open access) in community | 7207 | 5.46 SD 2.42
Neil, 2009^2^ | Depression score (Pre-test) | Use of website (open access) in classroom | 1000 | 2.62 SD 2.42
Neil, 2009^2^ | Anxiety (Pre-test) | Use of website (open access) in community | 7207 | 5.50 SD 2.59
Neil, 2009^2^ | Anxiety (Pre-test) | Use of website (open access) in classroom | 1000 | 2.51 SD 2.44
Neil, 2009^2^ | Warpy thoughts score | Use of website (open access) in community | 7207 | 3.16 SD 0.71
Neil, 2009^2^ | Warpy thoughts score | Use of website (open access) in classroom | 1000 | 2.58 SD 0.65
Neil, 2009^2^ | No. of exercises completed (0—28) | Use of website (open access) in community | 7207 | 3.10 SD 3.85 | | | | | | P < 0.001
Neil, 2009^2^ | No. of exercises completed (0—28) | Use of website (open access) in classroom | 1000 | 9.38 SD 6.84
Warmerda, 2008^3^ | Depression (CES – D) | Wait-listed controls (87) | 87 | 32.1 (9.3) | 25.6 (9.9) | 25.2 (9.9) | | 25.8 (10.4) | | Significant improvement with time. Yellow indicates significant difference
Warmerda, 2008^3^ | Depression (CES – D) | Interactive computer tool based on Cog. Beh. Theory (88) | 88 | 31.2 (9.3) | 22.9 (10.6) | 19.4 (11.3) | | 17.9 (11.7) | | Significant improvement with time. Yellow indicates significant difference
Warmerda, 2008^3^ | Depression (CES – D) | Interactive computer tool based on Prob. Sol. Theory (88) | 88 | 31.9 (9.3) | 20.6 (11.2) | 20.6 (11.3) | | 18.4 (12.1) | | Significant improvement with time. Yellow indicates significant difference
Warmerda, 2008^3^ | Anxiety using HADS | Wait-listed controls (87) | 87 | 11.3 (3.6) | 8.9 (3.9) | 9.0 (3.8) | | 8.9 (4.0) | | Significant improvement with time. Yellow indicates significant difference
Warmerda, 2008^3^ | Anxiety using HADS | Interactive computer tool based on Cog. Beh. Theory (88) | 88 | 10.6 (3.6) | 7.8 (4.1) | 6.7 (4.4) | | 6.6 (4.5) | | Significant improvement with time. Yellow indicates significant difference
Warmerda, 2008^3^ | Anxiety using HADS | Interactive computer tool based on Prob. Sol. Theory (88) | 88 | 10.2 (3.6) | 7.1 (4.3) | 6.9 (4.4) | | 6.6 (4.7) | | Significant improvement with time. Yellow indicates significant difference
Warmerda, 2008^3^ | QoL using EQ5D | Wait-listed controls (87) | 87 | 0.59 (0.18) | 0.69 (0.27) | 0.65 (0.27) | | 0.66 (0.27) | | Significant improvement with time. Yellow indicates significant difference
Warmerda, 2008^3^ | QoL using EQ5D | Interactive computer tool based on Cog. Beh. Theory (88) | 88 | 0.64 (0.18) | 0.68 (0.27) | 0.73 (0.27) | | 0.76 (0.27) | | Significant improvement with time. Yellow indicates significant difference
Warmerda, 2008^3^ | QoL using EQ5D | Interactive computer tool based on Prob. Sol. Theory (88) | 88 | 0.59 (0.18) | 0.73 (0.27) | 0.73 (0.27) | | 0.76 (0.27) | | Significant improvement with time. Yellow indicates significant difference
Warmerda, 2008^3^ | Depression (CES – D) Proportion reaching clinically significant change | Wait-listed controls (87) | 87 | | E: 0 (0.0) O: 10 (14.1) | E:0 (0.0) O: 15 (21.1) | | E: 0 (0.0) O: 9 (14.3) | | Brackets is %
Warmerda, 2008^3^ | Depression (CES – D) Proportion reaching clinically significant change | Interactive computer tool based on Cog. Beh. Theory (88) | 88 | | E: 0 (0.0) O: 11 (18.0) | E: 26 (29.5) O: 21 (41.2) | | E: 34 (38.6) O: 18 (39.1) | | Brackets is %
Warmerda, 2008^3^ | Depression (CES – D) Proportion reaching clinically significant change | Interactive computer tool based on Prob. Sol. Theory (88) | 88 | | E: 18 (20.5) O: 19 (36.5) | E: 18 (20.5) O: 20 (39.2) | | E: 30 (34.1) O: 17 (40.5) | | Brackets is %
Christensen, 2004^4^ | Center for Epidemiologic depression scale | Control | 159 | Mean score point improvement over baseline mean, 21.6 SD, 11.1 | | | | 6 weeks: mean, 1.1 SD, 8.4
Christensen, 2004^4^ | Center for Epidemiologic depression scale | Blue Pages: Computer based psycho education website offering information about depression | 136 | Mean score point improvement over baseline mean, 21.1 SD, 10.4 | | | | 6 weeks: mean, 3.9 SD, 9.1
Christensen, 2004^4^ | Center for Epidemiologic depression scale | Mood GYM: Computer based Cognitive Behavior therapy | 136 | Mean score point improvement over baseline mean, 21.8 SD, 10.5 | | | | 6 weeks: mean, 4.2 SD, 9.1
Christensen, 2004^4^ | Automatic thoughts | Control | 159 | Mean score point improvement over baseline | | | | 6 weeks mean, 3.1 SD, 15.8
Christensen, 2004^4^ | Automatic thoughts | Blue Pages: Computer based psycho education website offering information about depression | 136 | Mean score point improvement over baseline | | | | 6 weeks mean, 6.4 SD, 18.1
Christensen, 2004^4^ | Automatic thoughts | Mood GYM: Computer based Cognitive Behavior therapy | 136 | Mean score point improvement over baseline | | | | 6 weeks mean, 9.3 SD, 16.9
Christensen, 2004^4^ | Medical literacy | Control | 159 | Mean score point improvement over baseline | | | | 6 weeks mean, −0.1 SD, 0.5
Christensen, 2004^4^ | Medical literacy | Blue Pages: Computer based psycho education website Offering information about depression | 136 | Mean score point improvement over baseline | | | | 6 weeks mean, −0.6 SD, 0.7
Christensen, 2004^4^ | Medical literacy | Mood GYM: Computer based cognitive behavior therapy | 136 | Mean score point improvement over baseline | | | | 6 weeks mean, −0.1 SD, 0.5
Christensen, 2004^4^ | Psychological literacy | Control | 159 | Mean score point improvement over baseline | | | | 6 weeks mean, −0 SD, 0.9
Christensen, 2004^4^ | Psychological literacy | Blue Pages: Computer based psycho education website offering information about depression | 136 | | | | | 6 weeks mean, −0.7 SD, 1.1
Christensen, 2004^4^ | Psychological literacy | Mood GYM: Computer based cognitive behavior therapy | 136 | | | | | 6 weeks mean, −0.5 SD, 1
Christensen, 2004^4^ | Lifestyle literacy | Control | 159 | Mean score point improvement over baseline | | | | 6 weeks: mean, 0.1 SD, 1.6
Christensen, 2004^4^ | Lifestyle literacy | Blue Pages: Computer based psycho education website offering information about Depression | 136 | Mean score point improvement over baseline | | | | 6 weeks: mean, −1.1 SD, 2
Christensen, 2004^4^ | Lifestyle literacy | Mood GYM: Computer based cognitive behavior therapy | 136 | Mean score point improvement over baseline | | | | 6 weeks: mean, −0 SD, 0.5
Christensen, 2004^4^ | Cognitive behavior therapy literacy | Control | 159 | Mean score point improvement over baseline | | | | 6 weeks mean, 0.1 SD, 1.6
Christensen, 2004^4^ | Cognitive behavior therapy literacy | Blue Pages: Computer based psycho education website offering information about depression | 136 | Mean score point improvement over baseline | | | | 6 weeks mean, −1.1 SD, 2
Christensen, 2004^4^ | Cognitive behavior therapy literacy | Mood GYM: Computer based cognitive behavior therapy | 136 | Mean score point improvement over baseline | | | | 6 weeks mean, −2 SD, 2.4
Phobia
Schneider, 2005^5^ | Main problem(self-rating) | Control | 13 | Mean, 7.2 SD, 1.4 | Week 10 mean, 4.9 SD, 2 | | | Week 14: mean, 4.9 SD, 1.7
Schneider, 2005^5^ | Main problem(self-rating) | Computer aided cognitive behavior therapy with self-help exposure | 31 | Mean, 7 SD, 1.2 | Week 10 mean, 4.7 SD, 2 | | | Week 14: mean, 4.1 SD, 2.1
Schneider, 2005^5^ | Main goal(self-rating) | Control | 13 | Mean, 7.3 SD, 1.6 | Week 10 mean, 4.8 SD, 2 | | | Week 14 mean, 5 SD, 1.9
Schneider, 2005^5^ | Main goal(self-rating) | Computer aided cognitive behavior therapy with self-help exposure | 31 | Mean, 7 SD, 1.2 | Week 10 Mean, 4.5 SD, 2.4 | | | Week 14 mean, 4.2 SD, 2.2
Stress
Chiauzzi, 2008^6^ | Perceived Stress Scale | Control | 78 | | | | | 7 months | | 0.77
Chiauzzi, 2008^6^ | Perceived Stress Scale | MyStudent Body–Stress website | 77 | | | | | 7 months
Chiauzzi, 2008^6^ | Perceived Stress Scale | No treatment control (NTX) | 80 | | | | | 7 months
Hasson, 2005^7^ | Self rated stress management | Control | 156 | Changes in self rated measures and biological markers covariate for baseline scores | | | | 6 month follow-up: mean, SD, | | Time*group effect= .001
Hasson, 2005^7^ | Self rated stress management | Web-based stress management system | 121 | Changes in self rated measures and biological markers covariate for baseline scores | | | | 6 month follow-up: mean, SD, | | Time*group effect= .001
Hasson, 2005^7^ | Self rated sleep quality | Control | 156 | Changes in self rated measures and biological markers covariate for baseline scores | | | | 6 month follow-up | | Time*group effect=.04
Hasson, 2005^7^ | Self rated sleep quality | Web-based stress management system | 121 | Changes in self rated measures and biological markers covariate for baseline scores | | | | 6 month follow-up | | Time*group effect=.04
Hasson, 2005^7^ | Self rated mental energy | Control | 156 | Changes in self rated measures and biological markers covariate for baseline scores | | | | 6 month follow-up | | Time*group effect= .002
Hasson, 2005^7^ | Self rated mental energy | Web-based stress management system | 121 | Changes in self rated measures and biological markers covariate for baseline scores | | | | 6 month follow-up | | Time*group effect: .002
Hasson, 2005^7^ | Self rated concentration ability | Control | 156 | Changes in self rated measures and biological markers covariate for baseline scores | | | | 6 month follow-up | | Time*group effect: .038
Hasson, 2005^7^ | Self rated concentration ability | Web-based stress management system | 121 | | | | | 6 month follow-up | | BL, Time*group effect: .038
Hasson, 2005^7^ | Self rated social support | Control | 156 | Changes in self rated measures and biological markers covariate for baseline scores | | | | 6 month follow-up | | Time*group effect: .049
Hasson, 2005^7^ | Self rated social support | Web-based stress management system | 121 | Changes in self rated measures and biological markers covariate for baseline scores | | | | 6 month follow-up | | Time*group effect: .049
Hasson, 2005^7^ | Biological marker: dehydroeoiandosterone sulphate | Control | 156 | Changes in self rated measures and biological markers covariate for baseline scores | | | | 6 month follow-up | | Time*group effect: .04
Hasson, 2005^7^ | Biological marker: dehydroeoiandosterone sulphate | Web-based stress management system | 121 | Changes in self rated measures and biological markers covariate for baseline scores | | | | 6 month follow-up | | Time*group effect: .04
Hasson, 2005^7^ | Nero peptide | Control | 156 | Changes in self rated measures and biological markers covariate for baseline scores | | | | 6 month follow-up | | Time*group effect: .002
Hasson, 2005^7^ | Nero peptide | Web-based stress management system | 121 | Changes in self rated measures and biological markers covariate for baseline scores | | | | 6 month follow-up | | Time*group effect= .002
Hasson, 2005^7^ | Chromogranin | Control | 156 | Changes in self rated measures and biological markers covariate for baseline scores | | | | 6 month follow-up | | Time*group effect: .001
Hasson, 2005^7^ | Chromogranin | Web-based stress management system | 121 | Changes in self rated measures and biological markers covariate for baseline scores | | | | 6 month follow-up | | Time*group effect: .001
Zetterqvist, 2003^8^ | Perceived Stress Scale | Control | 40 | M 33.17 SD 3.76 | | | | M 28.88 SD 7.02 | | Significant difference
Zetterqvist, 2003^8^ | | Interactive self help stress management program | 23 | 32.91 SD 6.08 | | | | 24.48 SD 7.17
Zetterqvist, 2003^8^ | Hospital Anxiety and Depression Scale HADS | Control | 40 | 23.23 SD 5.85 | | | | 18.70 SD7.64
Zetterqvist, 2003^8^ | | Interactive self help stress management program | 23 | 23.61 SD 5.96 | | | | 14.13 SD 7.09
Zetterqvist, 2003^8^ | Anxiety | Control | 40 | 13.85 SD 4.12 | | | | 11.10 SD 5.05
Zetterqvist, 2003^8^ | | Interactive self help stress management program | 23 | 13.43 SD 4.00 | | | | 8.39 SD 4.50
Zetterqvist, 2003^8^ | Depression | Control | 40 | 9.38 SD 3.07 | | | | 7.60 SD 3.13
Zetterqvist, 2003^8^ | | Interactive self help stress management program | 23 | 10.17 SD 2.90 | | | | 5.74 SD 3.14
Zetterqvist, 2003^8^ | LE (Life Events) (Holmes and Rahes Scale) | Control | 40 | 1.55 SD 1.22 | | | | 1.60 SD 1.28
Zetterqvist, 2003^8^ | | Interactive self help stress management program | 23 | 1.52 SD 1.38 | | | | 1.48 SD 1.38
Zetterqvist, 2003^8^ | Perceived Social Support PS-family | Control | 40 | 9.80 SD 3.45 | | | | 9.62 SD 3.62
Zetterqvist, 2003^8^ | | Interactive self help stress management program | 23 | 8.48 SD 3.46 | | | | 8.61 SD 3.63
Zetterqvist, 2003^8^ | Perceived Social Support PS-friends | Control | 40 | 9.40 SD 3.26 | | | | 9.82 SD 3.99
Zetterqvist, 2003^8^ | | Interactive self help stress management program | 23 | 9.78 SD 3.66 | | | | 10.09 SD 4.01

BL = baseline, SD = standard deviation, BDI = Beck Depression Inventory, BAI = Beck Anxiety Inventory, ASQ C0Neg/CoPos = Attribution Style Questionnaire, composite index for negative/positive situations

Reference List

1 Proudfoot J, Ryden C, Everitt B et al. Clinical efficacy of computerised cognitive-behavioural therapy for anxiety and depression in primary care: randomised controlled trial. Br J Psychiatry 2004; 185:46–54.

2 Neil AL, Batterham P, Christensen H, Bennett K, Griffiths KM. Predictors of adherence by adolescents to a cognitive behavior therapy website in school and community-based settings. J Med Internet Res 2009; 11(1):e6.

3 Warmerdam L, van Straten A, Twisk J, Riper H, Cuijpers P. Internet-based treatment for adults with depressive symptoms: randomized controlled trial. J Med Internet Res 2008; 10(4):e44.

4 Christensen H, Griffiths KM, Jorm AF. Delivering interventions for depression by using the internet: randomised controlled trial. BMJ 2004; 328(7434):265.

5 Schneider AJ, Mataix-Cols D, Marks IM, Bachofen M. Internet-guided self-help with or without exposure therapy for phobic and panic disorders. Psychother Psychosom 2005; 74(3):154–64.

6 Chiauzzi E, Brevard J, Thurn C, Decembrele S, Lord S. MyStudentBody-Stress: an online stress management intervention for college students. J Health Commun 2008; 13(6):555–72.

7 Hasson D, Anderberg UM, Theorell T, Arnetz BB. Psychophysiological effects of a web-based stress management system: a prospective, randomized controlled intervention study of IT and media workers. BMC Public Health 2005; 5:78.

8 Zetterqvist K, Maanmies J, Str+¦m L, Andersson G. Randomized controlled trial of internet-based stress management. 2003; 32(3):151–60.

Evidence Table 26

Description of RCTs addressing the impact of CHI applications on intermediate outcomes in asthma and COPD (KQ1b)

Author, year | Consumer under study | CHI Application type | Location | Year data collected/duration of intervention | Inclusion criteria | Exclusion criteria | Control | Intervention | Jadad score
Asthma
Jan, 2007^1^ | Individuals interested in their own health care Caregiver, childhood asthma | Personal monitoring device | Home/residence | 2004/January to December | 6 – 12 yr, Caregivers have Internet access, Persistent asthma diagnosis (GINA clinical practice guidelines) | Diagnosed with bronchopulmonary dysplasia, Diagnosed with other chronic co morbid conditions that could affect quality of life | Verbal information and booklet for asthma education with written asthma diary. | Blue Angel for Asthma Kids An Internet-based diary record for peak expiratory flow rate Symptomatic support information, and an action plan suggestion, and telecommunication technologies for uploading and retrieving the storage data | 1.5
Joseph, 2007^2^ | Individuals interested in their own health care | Interactive consumer website | Remote location: school | NS | 9–11 grade, Current asthma | | Generic asthma website | Tailored website | 2.5
Krishna, 2003^3^ | Individuals interested in their own healthd Caregiver: Parents/caregivers | Personal monitoring device | Home/residence | 1999/NS | <18 yr, Confirmed asthma | Cystic fibrosis, Bronchopulmonary dysplasia, Other chronic lung disease | Traditional care | Internet-enabled interactive multimedia asthma education program | 1
COPD
Nguyen, 2008^4^ | Individuals interested in their own health care | Interactive consumer website | Academic medical centers | 2005 | Diagnosis of COPD and being clinically stable for at least 1 month, Spirometry results showing at least mild obstructive disease, ADL limited by dyspnea, Use of the Internet and/or checking email at least once per week with a windows operating system, Oxygen saturation > 85% on room air or ¡Ü 6 L/min of nasal oxygen at the end of a 6-minute walk test | Any active symptomatic illness, Participated in a pulmonary rehabilitation program in the last 12 months, Were currently participating in > 2 days of supervised maintenance exercise | Face-to-face (fDSMP) | Internet-based (eDSMP) | 2.5

NS = not specified, yr = year, PEFR = Peak expiratory flow rate, COPD = Chronic obstructive pulmonary disease, ADL = Activities of daily living, eDSMP = Internet based dyspnea self-management programs, fDSMP = face-to-face dyspnea self-management programs, min = minutes

Reference List

1 Jan RL, Wang JY, Huang MC, Tseng SM, Su HJ, Liu LF. An internet-based interactive telemonitoring system for improving childhood asthma outcomes in Taiwan. Telemed J E Health 2007; 13(3):257–68.

2 Joseph CL, Peterson E, Havstad S et al. A web-based, tailored asthma management program for urban African-American high school students. Am J Respir Crit Care Med 2007; 175(9):888–95.

Notes: CORPORATE NAME: Asthma in Adolescents Research Team

3 Krishna S, Francisco BD, Balas EA, Konig P, Graff GR, Madsen RW. Internet-enabled interactive multimedia asthma education program: a randomized trial. Pediatrics 2003; 111(3):503–10.

Notes: CORPORATE NAME: Randomized trial

4 Nguyen HQ, Donesky-Cuenco D, Wolpin S et al. Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res 2008; 10(2):e9.

Evidence Table 27

Description of consumer characteristics in studies addressing the impact of CHI applications on intermediate outcomes in asthma and COPD (KQ1b)

Author, year | Control Interventions | Age | Race, n (%) | Income | Education, n (%) | SES | Gender, n (%) | Other characteristics
Asthma
Jan, 2007^1^ | Verbal information and booklet for asthma education with written asthma diary | Mean, 9.9 SD, 3.2 | NS | NS | Education of primary caregiver: HS diploma or below, 43 (56.6) College or above, 33 (43.4) | NR | M, 28(36.8) F, 48(63.2) | History of asthma (yr): mean, 2.1 SD, 1.2 Asthma severity: mild, 33(43.4) moderate, 35(46.1) severe, 8(10.5)
Jan, 2007^1^ | Participants received asthma education and with interactive asthma monitoring system | Mean, 10.9 SD, 2.5 | NS | NS | Education of primary caregiver: HS diploma or below, 58(66.0) College or above, 30 (34.0) | NR | M, 35(39.7) F, 53(60.2) | History of asthma (yr): mean, 2.4 SD, 1.9 Asthma severity: mild, 33(37.5) moderate, 43(48.9) severe, 12(13.6)
Joseph, 2007^*,2^ | Generic asthma website | Mean, 15.3 SD, 1 | NS | USD mean, 12,049 SD, 2,442 | NS | NR | F, 199 (63.4)
Joseph, 2007^*,2^ | Tailored website | Mean, 15.3 SD, 1 | NS | USD mean, 12,049 SD, 2,442 | NS | NR | F, 199 (63.4)
Krishna, 2003^†,3^ | Traditional care | Range, 0–17 yr | White non-Hispanic, 102(84.3) Black non-Hispanic, 9(7.4) AIAN, 7(5.8) Other, 3 | NS | Preschool/none: 58 (47.9) Kindergarten: 6(5) Elementary: 27(22.3) Jr High 24 (19.8) High School 6 (5) | NR | M, 76 (62.8) F, 45 (37.2)
Krishna, 2003^†,3^ | Internet-enabled interactive multimedia asthma education program | Range, 0–17 yr | White non-Hispanic, 93(86.9) Black non-Hispanic, 10(9.3) AIAN, 2(1.9) Other, 2(1.9) | NS | Preschool/none: 48 (44.9) Kindergarten: 12(11.2) Elementary: 23 (21.5) Jr High 19 (17.6) High school 5 (4.1) | NR | M, 72 (67.3) F, 35 (32.7)
COPD
Nguyen, 2008^4^ | Face-to-face (fDSMP), | Mean, 70.9 SD, 8.6 | White non-Hispanic, 20(100) | NS | 12–16 yr, 8(40) >16yr, 12(60) | Not currently employed or currently disabled or retired: 15 (75) | F, 9 (45) | Currently smoking: 1 (5)
Nguyen, 2008^4^ | eDSMP | Mean, 68 SD, 8.3 | White non-Hispanic, 18 (95) | NS | 12–16 yr, 10(50) >16yr, 9(50) | Not currently employed or currently disabled or retired: 13 (72) | F, 8(39) | Currently smoking: 2 (11)

* Consumer characteristics were not stratified by intervention

† Education of caregiver was not reported

NS = not specified, SES = Socioeconomic Status, F = female, M = male, AIAN = American Indian/Alaska Native, Yr = year, SD = standard deviation, NR= Not Reported

USD = United States dollar, eDSMP = Internet-based dyspnea self-management programs, fDSMP = face to face dyspnea self management programs

Reference List

1 Jan RL, Wang JY, Huang MC, Tseng SM, Su HJ, Liu LF. An internet-based interactive telemonitoring system for improving childhood asthma outcomes in Taiwan. Telemed J E Health 2007; 13(3):257–68.

2 Joseph CL, Peterson E, Havstad S et al. A web-based, tailored asthma management program for urban African-American high school students. Am J Respir Crit Care Med 2007; 175(9):888–95.

3 Krishna S, Francisco BD, Balas EA, Konig P, Graff GR, Madsen RW. Internet-enabled interactive multimedia asthma education program: a randomized trial. Pediatrics 2003; 111(3):503–10.

4 Nguyen HQ, Donesky-Cuenco D, Wolpin S et al. Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res 2008; 10(2):e9.

Evidence Table 28

Outcomes in studies addressing the impact of CHI applications on intermediate outcomes of asthma and COPD (KQ1b)

Author, year | Outcomes | Control Intervention | n | Measure at BL | Measure at time point 2 | Measure at final time point | ratios at time points | Significance
Asthma
Jan, 2007^1^ | Monitoring adherence (peak flow meter technique score (%)) | Control | 71 | 85.6 | NA | 12 week, 93.5 | NA
Jan, 2007^1^ | Monitoring adherence (peak flow meter technique score (%)) | Education and interactive asthma monitoring system | 82 | 83.5 | NA | 12 week, 99.7 | NA
Jan, 2007^1^ | Monitoring adherence (asthma diary entries per month) | Control | 71 | Mean, 21 SD, 4.5 | NA | 12 weeks, mean, 15 SD, 5.3 | NA | Significantly different from BL value
Jan, 2007^1^ | Monitoring adherence (asthma diary entries per month) | Education and interactive asthma monitoring system | 82 | Mean, 27 SD, 3.2 | NA | 12 weeks, mean, 23 SD, 4.3 | NA
Jan, 2007^1^ | Monitoring adherence (adherence to asthma diary (%)) | Control | 71 | 93.2 | NA | 12 weeks, 53.4 | NA
Jan, 2007^1^ | Monitoring adherence (adherence to asthma diary (%)) | Education and interactive asthma monitoring system | 82 | 96.0 | NA | 12 weeks, 82.5 | NA
Jan, 2007^1^ | Therapeutic adherence (DPI or MDI plus spacer technique score (%)) | Control | 71 | 80.3 | NA | 12 week, 93.1 | NA
Jan, 2007^1^ | Therapeutic adherence (DPI or MDI plus spacer technique score (%)) | Education and interactive asthma monitoring system | 82 | 82.1 | NA | 12 week, 96.5 | NA
Jan, 2007^1^ | Therapeutic adherence (adherence to inhaled corticosteroid, (%)) | Control | 71 | 82.3 | NA | 12 week, 42.1 | NA
Jan, 2007^1^ | Therapeutic adherence (adherence to inhaled corticosteroid, (%)) | Education and interactive asthma monitoring system | 82 | 83.5 | NA | 12 week, 63.2 | NA
Joseph , 2007^2^ | Controller medication adherence: positive behavior change | Control | 143 | NR | NA | 12 months, n(%) 18 (12.6) | NA | 0.09
Joseph , 2007^2^ | Controller medication adherence: positive behavior change | Puff City internet intervention | 152 | NR | NA | 12 months, n(%) 31 (20.4) | NA | 0.09
Joseph , 2007^2^ | Controller medication adherence: no change in negative behavior | Control | 143 | NR | NA | 12 months, n(%) 91 (63.6) | NA | 0.09
Joseph , 2007^2^ | Controller medication adherence: no change in negative behavior | Puff City internet intervention | 152 | NR | NA | 12 months, n(%) 95 (62.5) | NA | 0.09
Joseph , 2007^2^ | Controller medication adherence: negative change in behavior | Control | 143 | NR | NA | 12 months, n(%) 34 (23.8) | NA | 0.09
Joseph , 2007^2^ | Controller medication adherence: negative change in behavior | Puff City internet intervention | 152 | NR | NA | 12 months, n(%) 26 (17.1) | NA | 0.09
Joseph , 2007^2^ | Rescue inhaler availability: positive behavior change | Control | 143 | NR | NA | 12 months, n(%) 46 (32.2) | NA | 0.01
Joseph , 2007^2^ | Rescue inhaler availability: positive behavior change | Puff City internet intervention | 152 | NR | NA | 12 months, n(%) 59 (38.8) | NA | 0.01
Joseph , 2007^2^ | Rescue inhaler availability: no change in negative behavior | Control | 143 | NR | NA | 12 months, n (%) 62 (43.3) | NA | 0.01
Joseph , 2007^2^ | Rescue inhaler availability: no change in negative behavior | Puff City internet intervention | 152 | NR | NA | 12 months, n (%) 74 (48.7) | NA | 0.01
Joseph , 2007^2^ | Rescue inhaler availability: negative change in behavior | Control | 143 | NR | NA | 12 months, n (%) 35 (24.5) | NA | 0.01
Joseph , 2007^2^ | Rescue inhaler availability: negative change in behavior | Puff City internet intervention | 152 | NR | NA | 12 months, n (%) 19 (12.5) | NA | 0.01
Krishna, 2003^3^ | Asthma Knowledge score (caregivers of children 0–6yr) | Control | 23 | Mean, 48.41 SD, 6.64 | NA | 12 months mean, 52.3 SD, 5.55 | NA | <0.01
Krishna, 2003^3^ | Asthma Knowledge score (caregivers of children 0–6yr) | Interactive asthma education | 24 | Mean, 47.94 SD, 5.24 | NA | 12 months mean, 55.68 SD, 4.28 | NA | <0.01
Krishna, 2003^3^ | Asthma knowledge score (caregivers of children 7–17yr) | Control | 28 | Mean, 49.57 SD, 4.75 | NA | 12 months mean, 55.38 SD, 4.16 | NA | <0.01
Krishna, 2003^3^ | Asthma knowledge score (caregivers of children 7–17yr) | Interactive asthma education | 26 | Mean, 49.95 SD, 5.59 | NA | 12 months mean, 55.68 SD, 4.28 | NA | <0.01
Krishna, 2003^3^ | Asthma knowledge score (children 7–17yr) | Control | 28 | Mean, 43.44 SD, 4.75 | NA | 12 months mean, 47.51 SD, 5.95 | NA | <0.001
Krishna, 2003^3^ | Asthma knowledge score (children 7–17yr) | Interactive asthma education | 25 | Mean, 49.95 SD, 6.10 | NA | 12 months mean, 53.12 SD, 5.56 | NA
Krishna, 2003^3^ | Change in knowledge(caregivers of children 0–6yr) | Control | 23 | | NA | mean, 2.52 SD, 6.71 median, 5 95% CI, −0.38 to 5.42 | NA | 0.0293
Krishna, 2003^3^ | Change in knowledge(caregivers of children 0–6yr) | Interactive asthma education | 24 | | NA | mean, 7.97 SD, 4.57 median, 7 95% CI, 5 to 11 | NA | <0.0001
Krishna, 2003^3^ | Change in knowledge (caregivers of children 7–17yr) | Control | 28 | | NA | mean, 2.38 SD, 4.38 median, 2.55 95% CI, 0 to 4 | NA | 0.0079
Krishna, 2003^3^ | Change in knowledge (caregivers of children 7–17yr) | Interactive asthma education | 26 | | NA | mean, 4.62 SD, 4.48 median, 3 95% CI, 2 to 7 | NA | <0.0001
Krishna, 2003^3^ | Change in knowledge (children 7–17yr) | Control | 27 | | NA | mean, 4.44 SD, 5.49 median, 4 95% CI, 2 to 7 | NA | 0.0001
Krishna, 2003^3^ | Change in knowledge (children 7–17yr) | Interactive asthma education | 25 | | NA | mean, 10 SD, 6.99 median, 8 95% CI, 7 to 11 | NA | <0.0001
COPD
Nguyen, 2008^4^ | Dyspnea knowledge score (range 0–15) | Face-to-face dyspnea self-management program | 20 | Mean, 12.5 SD, 2.3 | 3 months mean,13.3 SD, 1.6 | 6 months mean,13.8 SD, 1.5 | NA | Group P: 0.49 time P value: <0.001 group X time P value: 0.68
Nguyen, 2008^4^ | Dyspnea knowledge score (range 0–15) | Internet-based dyspnea self-management program | 19 | Mean, 12.6 SD, 1.8 | 3 months mean, 13.8 SD,1.0 | 6 months mean, 14.1 SD, 1.0 | NA | Group P: 0.49 time P value: <0.001 group X time P value: 0.68
Nguyen, 2008^4^ | Self-efficacy score for managing dyspnea (range 0–10) | Face-to-face dyspnea self-management program | 20 | Mean, 4.6 SD, 2.4 | 3 months mean, 5.5 SD,3.3 | 6 months mean, 5.0 SD, 3.6 | NA | Group P: 0.18 time P value: 0.2 group X time P value: 0.34
Nguyen, 2008^4^ | Self-efficacy score for managing dyspnea (range 0–10) | Internet-based dyspnea self-management program | 19 | Mean, 4.7 SD, 2.3 | 3 months mean, 6.8 SD,2.3 | 6 months mean, 6.7 SD, 2.6 | NA | Group P: 0.18 time P value: 0.2 group X time P value: 0.34

NS = not specified, NA = not applicable, yr = year, SD = standard deviation, BL = baseline, NR = not reported

Reference List

1 Jan RL, Wang JY, Huang MC, Tseng SM, Su HJ, Liu LF. An internet-based interactive telemonitoring system for improving childhood asthma outcomes in Taiwan. Telemed J E Health 2007; 13(3):257–68.

2 Joseph CL, Peterson E, Havstad S et al. A web-based, tailored asthma management program for urban African-American high school students. Am J Respir Crit Care Med 2007; 175(9):888–95.

3 Krishna S, Francisco BD, Balas EA, Konig P, Graff GR, Madsen RW. Internet-enabled interactive multimedia asthma education program: a randomized trial. Pediatrics 2003; 111(3):503–10.

4 Nguyen HQ, Donesky-Cuenco D, Wolpin S et al. Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res 2008; 10(2):e9.

Evidence Table 29

Description of RCTs addressing the impact of CHI applications on intermediate outcomes on miscellaneous topic

Author, year | Consumer under study | CHI Application type | Location | Year data collected/duration of intervention | Inclusion criteria | Exclusion criteria | Control | Intervention | Jadad score
CVD
Kukafka, 2002^1^ | Individuals interested in their own health care | Interactive consumer website | NS | NS | Unspecified AMI risk criteria | | | Tailored Web-based, Non-tailored Web-based Non-tailored paper based. | −1
Simkins, 1986^2^ | Individuals interested in their own health care | Electronic medication reminder | Primary care or specialty clinics at an university health care | Duration, 3 months | 64–67yr | | Group 1 | Group 2, Group 3 | 3
Arthritis
Lorig, 2008^3^ | Individuals interested in their own health care | Interactive consumer website | NS | 2004/NS | 18 and older, a diagnosis of OA, rheumatoid arthritis (RA), or fibromyalgia, could have other chronic conditions Internet and email access agreed to 1–2 hours per week of log-on time spread over at least 3 sessions/week for 6 weeks | Active treatment for cancer for 1 year, participated in the small-group ASMP or the Chronic Disease Self-Management Program | Usual care | Online intervention | 1
Back pain
Buhrman,2004^4^ | Individuals interested in their own health care | Interactive consumer website | Home/residence | NS | 18–65 years old, Internet access, been in contact with a physician, have back pain, have chronic pain (>3 months) | Suffer of pain that can increase as a consequence of activity, wheelchair bound, have planned any surgical treatment, suffer from heart and vascular disease | Wait-list | Internet-based pain management program | 2
Behavioral risk factors
Oenema, 2008^5^ | Individuals interested in their own health care | Personalized health risk assessment tool | NS | 2004/NS | 30 years or older, Dutch adults, Internet skills, sufficient understanding of the Dutch language | Insufficient understanding of the Dutch language, poor Internet skills | Control group | Internet group | 3
Breast cervical prostate and laryngeal cancer
Jones, 1999^6^ | Individuals interested in their own health care | Interactive consumer website | Clinician office | 1996/NS | Breast, laryngeal, prostate, cervical cancer patients receiving care at oncology center, | Receiving palliative treatment, no knowledge of diagnosis, visual or mental handicap, severe pain | Booklet information | Personalized computer information General computer information | 1
Cervical cancer
Campbell, 1997^7^ | Individuals interested in their own health care | Personalized health risk assessment tool | Clinician office | 1995/NS | Between 18 and 70 years, can speak and read English well enough to use computer | | Survey without computer generated printed feed back | Survey with computer generated printed feed back | −1
Cancer, Prostate
Forsch, 2008^8^ | Individuals interested in their own health care | Interactive consumer website | Home/residence | 2005 | >50 yr, Men | | Control | Traditional decision aid Chronic disease trajectory model combined | 2
Caregiver decision making
Brennan, 1995^9^ | Caregivers of persons with Alzheimer’s Disease | Interactive consumer website | Home/residence | NS | Primary responsibility as a family caregiver for a person with Alzheimer’s disease living at home, has a local telephone exchange, the ability to read and write English | | Comparison group | Computer link program | 2
Change in health behavior
Harari, 2008^10^ | Individuals interested in their own health care | Personalized health risk assessment tool | NS | 2001/NS | 65 and older | Nursing home resident, needing help in basic activities of daily living, dementia, terminal disease, non-English speaking | Usual care control group | HRA-O intervention group | 1
Paperny, 1990^11^ | Adolescent with high risk behavior | Personalized health risk assessment tool | Clinician office | Duration 3 years | Voluntary participation, both male and female, Teen agers | Participants unwillingness | Group Q: 251 participants those who has given a written questionnaire before physical exam and printout shared with the clinician | Group (1): 265 participants those who was given computer questionnaire after the physical exam and printout remain private Group (2): 294 participants those who was given computer questionnaire before the physical exam and printout shared with clinician
Headache
Devineni, 2005^12^ | Individuals interested in their own health care | Personal monitoring device | Home/residence | | Chronic tension or migraine HA for at least one year | New headache onset within the past year, head injury or major illness in temporal proximity to headache onset, Secondary headache diagnosis, Concurrent chronic pain disorder other than primary migraine or tension headache | Delayed | Treatment | 2
HIV/AIDS
Flatley-Brennan, 1998^13^ | Individuals interested in their own health care | Interactive consumer website | Home/residence | NS | HIV infected, ability to read and type English, home telephone line | | Received brochure | Received computer intervention
Menopause HRT
Rostom, 2002^14^ | Individuals interested in their own health care | Computerized decision aid | Home/residence | NS | 40–70, women, pre and post menopausal, fully fluent in spoken and written English, no evidence of cognitive impairment or psychiatric illness | | Audio booklet | Interactive computerized DA | 0
Schapira, 2007^15^ | Individuals interested in their own health care | Personalized health risk assessment tool | Clinician office | May 2002–Oct 2003 | 45–74 yr, female, post menopausal, VA clinic patient | Non English speaking, MMSE < 23 | Printed pamphlet | Computer-based decision aid | 2
Preventing falls in the elderly
Yardley,2007^16^ | Individuals interested in their own health care | Interactive consumer website, | NS | July–Dec 2005 | | <65 yr, used site more than once | | | 5
Use of contraception
Chewning, 199^17^ | Individuals interested in their own health care | Computer based decision Aid | Clinician office | NS | ≤ 20 years, Female, ability to read and understand English, expressed interest in getting a contraceptive | | Standard information | Computer based interactive decision aid | 0

NS = Not specified, OA = Osteoarthritis, RA = rheumatoid arthritis, CHESS = Comprehensive Health Enhancement Support System, Yr = year

Reference List

1 Kukafka R, Lussier YA, Eng P, Patel VL, Cimino JJ. Web-based tailoring and its effect on self-efficacy: results from the MI-HEART randomized controlled trial. Proc AMIA Symp 2002; 410–4.

2 Simkins CV, Wenzloff NJ. Evaluation of a computerized reminder system in the enhancement of patient medication refill compliance. Drug Intell Clin Pharm 1986; 20(10):799–802.

3 Lorig KR, Ritter PL, Laurent DD, Plant K. The internet-based arthritis self-management program: a one-year randomized trial for patients with arthritis or fibromyalgia. Arthritis Rheum 2008; 59(7):1009–17.

4 Buhrman M, Faltenhag S, Strom L, Andersson G. Controlled trial of Internet-based treatment with telephone support for chronic back pain. Pain 2004; 111(3):368–77.

5 Oenema A, Brug J, Dijkstra A, de Weerdt I, de Vries H. Efficacy and use of an internet-delivered computer-tailored lifestyle intervention, targeting saturated fat intake, physical activity and smoking cessation: a randomized controlled trial. Ann Behav Med 2008; 35(2):125–35.

6 Jones R, Pearson J, McGregor S et al. Randomised trial of personalised computer based information for cancer patients. BMJ 1999; 319(7219):1241–7.

7 Campbell E, Peterkin D, Abbott R, Rogers J. Encouraging underscreened women to have cervical cancer screening: the effectiveness of a computer strategy. Prev Med 1997; 26(6):801–7.

8 Frosch DL, Bhatnagar V, Tally S, Hamori CJ, Kaplan RM. Internet patient decision support: a randomized controlled trial comparing alternative approaches for men considering prostate cancer screening. Arch Intern Med 2008; 168(4):363–9.

9 Brennan PF, Moore SM, Smyth KA. The effects of a special computer network on caregivers of persons with Alzheimer’s disease. Nurs Res 1995; 44(3):166–72.

10 Harari D, Iliffe S, Kharicha K et al. Promotion of health in older people: a randomised controlled trial of health risk appraisal in British general practice. Age Ageing 2008; 37(5):565–71.

11 Paperny DM, Aono JY, Lehman RM, Hammar SL, Risser J. Computer-assisted detection and intervention in adolescent high-risk health behaviors. 1990; 116(3):456–62.

12 Devineni T, Blanchard EB. A randomized controlled trial of an internet-based treatment for chronic headache. Behav Res Ther 2005; 43(3):277–92.

13 Flatley-Brennan P. Computer network home care demonstration: a randomized trial in persons living with AIDS. Comput Biol Med 1998; 28(5):489–508.

14 Rostom A, O’Connor A, Tugwell P, Wells G. A randomized trial of a computerized versus an audio-booklet decision aid for women considering post-menopausal hormone replacement therapy. Patient Educ Couns 2002; 46(1):67–74.

15 Schapira MM, Gilligan MA, McAuliffe T, Garmon G, Carnes M, Nattinger AB. Decision-making at menopause: a randomized controlled trial of a computer-based hormone therapy decision-aid. Patient Educ Couns 2007; 67(1–2):100–7.

16 Yardley L, Nyman SR. Internet provision of tailored advice on falls prevention activities for older people: a randomized controlled evaluation. Health Promot Int 2007; 22(2):122–8.

17 Chewning B, Mosena P, Wilson D et al. Evaluation of a computerized contraceptive decision aid for adolescent patients. Patient Educ Couns 1999; 38(3):227–39.

Evidence Table 30

Description of consumer characteristics studies addressing the impact of CHI applications on intermediate outcomes in miscellaneous conditions

Author, year | Control Interventions | Age | Race, n(%) | Income | Education, n(%) | SES | Gender, n(%) | Marital Status, n(%) | Other
CVD
Kukafka, 2002^1^ | Control | NS | NS | NS | NS | NR | | | NS
Kukafka, 2002^1^ | tailored Web-based | NS | NS | NS | NS | NR | | | NS
Kukafka, 2002^1^ | Non-tailored Web-based | NS | NS | NS | NS | NR | | | NS
Simkins, 1986^2^ | Group1 | Mean, 64 | NS | NS | NS | NR | | | Chronic medication/patient: mean, 2.95
Simkins, 1986^2^ | Group 2 | Mean, 66 | NS | NS | NS | NR | | | Chronic medication/patient: mean, 3.09
Simkins, 1986^2^ | Group 3 | Mean, 67 | NS | NS | NS | NR | | | Chronic medication/patient: mean, 2.78
Arthritis
Lorig, 2008^3^ | Usual care | Mean, 52.5 range, 22–89 SD, 12.2 | White non-Hispanic, 425(93.7) | NS | Mean, 15.7 SD, 3.11 | NR | F, 425(90.5) | Married: 425(71.1) | Health-related Web site visits last 6 months: mean, 2.85 SD, 11.68
Lorig, 2008^3^ | Online intervention | Mean, 52.2 SD, 10.9 | White non-Hispanic, 441(90.9) | NS | Mean, 15.6 SD, 3.09 | NR | F, 441(89.8) | Married: 441(65.5) | Health-related Web site visits last 6 months: mean, 2.87 SD, 11.2
Back pain
Buhrman, 2004^4^ | Wait-list | Mean, 45 SD, 10.7 | NS | NS | <8 yr, 7(24.1) 8–12 yr, 6(21) 12–14 yr, 2 (6.9) 14–16 yr, 14 (48.3) | NR | M, 11 (37.9) F, 18 (62.1) | | Sick leave: Yes:12 (41.4) No:17 (58.6) Pain location: Back, 12 (41.4) Back plus other area, 17(58.6) Previous treatment: PT:11(37.9) Chiropractor:12 (41.4) Naprapathy:3 (10.3) Psychologist:6 (20.7) Pain Clinic:2 (6.9)
Buhrman, 2004^4^ | Internet-based pain management program | Mean, 43.5 SD, 10.3 | NS | NS | <8 yr, 2 (9.1) 8–12 yr, 6 (27) 12–14 yr, 3 (13.6) 14–16 yr, 11 (50) | NR | M, 8 (36.4) F, 14 (63.6) | | Sick leave: Yes: 5 (22.7) No: 17 (77.3) Pain location: Back, 7 (31.8) Back plus other area, 15 (68.2) Previous treatment: PT: 10 (45.5) Chiropractor: 8 (36.4) Nephropathy: 4 (18.2) Psychologist: 3 (13.6) Pain Clinic: 1 (4.5)
Behavioral risk factors
Oenema, 2008^5^ | Control group | Mean, 44.1 SD, 10.4 | NS | NS | Educational level: High 453 (42) Medium 324 (30) Low 302 (28) | NR | M, 507 (47) F, 572 (53)
Oenema, 2008^5^ | Internet group | Mean, 43.1 SD, 10.4 | NS | NS | Educational level: High 432 (40) Medium 3 67 (34) Low 281 (26) | NR | M, 497 (46) F, 583 (54)
Breast cervical prostate and laryngeal cancer
Jones, 1999^6^ | Booklet information | NS | NS | NS | NS | NS | NS | NS | NS
Jones, 1999^6^ | | NS | NS | NS | NS | NS | NS | NS | NS
Cervical cancer
Campbell, 1997^7^ | Survey without computer generated printed feed back | < 50 yr, (78) | Australian born, (94) | NS | 8–12 yr,(55) | NR | | Married or living with partner, (71) | Full/part time work, (44) NS
Campbell, 1997^7^ | intervention | NS | NS | NS | NS | NR | | | NS
Cancer, Prostate
Forsch, 2008^8^ | Control | Mean, 59 SD, 5.1 | White non-Hispanic, 133(880) Black non-Hispanic, 4(2.6) Latino/Hispanic, 6(4) API, 6(4) Not specified, 2 (1.3) | NS | High school or less 6(4) Some college44(29.1) College 42(27.8) Some graduate school 10(6.6) | NR | NS | Married 123(81.5) Other 28(18.5) | Internet access, n, (%): home 127(84.1) work 24(15.9)
Forsch, 2008^8^ | Traditional decision aid | Mean, 58.5 SD, 5.5 | White non-Hispanic, 133(85.8) Black non-Hispanic, 6(3.9) Latino/Hispanic, 7(4.5) API, 4(2.6) Not specified, 5 (3.2), | NS | High school or less 8(5.2) Some college 39(25.2) College44(28.4) Some graduate school13(8.4) | NR | NS | Married 119(76.8) Other 36(23.2) | Internet access, n. (%): home 136(87.7) work 19(12.3)
Forsch, 2008^8^ | Chronic disease trajectory model | Mean, 58.4 median, range, SD, 5.6 | White non-Hispanic, 127(83) Black non-Hispanic, 2(1.3) Latino/Hispanic, 15(9.8) API, 7(4.6) | NS | High school or less 6(3.9) Some college40(26.1) College 35(22.9) Some graduate school 12(7.8) | NR | NS | Married 114(74.5) Other 39(25.5) | Internet access, n, (%): home 130(85) work 12(15)
Caregiver decision making
Brennan, 1995^9^ | Comparison group | Mean, 64 | White non-Hispanic, (72) | NS | 12–16 yr, (86) | NR | F,(67)
Brennan, 1995^9^ | Experimental | NS | NS | NS | NS | NR | | | NS
Change in Health behavior
Harari, 2008^10^ | Usual care control group | Mean, 74.2 SD, 6 | NS | NS | NS | NR | F, 564(52.9) | | Fair or poor general-health perception: 271 (25.4) Ischemic heart disease: 175 (16.4) diabetes:73(6.9
Harari, 2008^10^ | HRA-O intervention group | Mean, 74.7 SD, 6.3 | NS | NS | NS | NR | F, 526(56.0) | | Fair or poor general-health perception: 207 (22.0) Ischemic heart disease: 170 (18.1) diabetes: 70(7.5)
Paperny, 1990^11^ | Control: Group Q: 251 participants those who has given a written questionnaire before physical exam and printout shared with the clinician | mean, 15.1 SD, 1.46 | White,(33) Hawaiian, (12) Oriental, (32) Pacific/mixture, (12) Other (11) | Financial assistance (10) | NR | NR | M, 131(52) | | NS
| Intervention Group (1): 265 participants those who was given computer questionnaire after the physical exam and printout remain private | mean, 14.9 SD, 1.44 | White (33) Hawaiian (13) Oriental (30) Pacific/mixture (13) Other (11) | (10) | NR | | M, 154(58)
| Group (2): 294 participants those who was given computer questionnaire before the physical exam and printout shared with clinician | mean, 15.0 SD, 1.37 | White (34) Hawaiian (14) Oriental (32) Pacific/mixture, (11) Other, (9) | (11) | NR | NR | M, 176 (60) | | NS
Headache
Devineni, 2005^12^ | Delayed | Mean, 43.6 SD, 11.8 | NS | NS | NS | NR | M, 10 (21) F, 37 (79) | | Headache Index score: Mean, 35.5 SD, 15.5 Medication Index: Mean, 0.85 SD 1.04 Yr computing: Mean, 5.8 SD, 3.6
Devineni, 2005^12^ | Treatment | Mean, 43.6 SD, 12 | NS | NS | NS | NR | M, 5 (12) F, 34 (88) | | HA Index: Mean 31.8 SD 17 Medication Index: Mean 0.93 SD 0.99 Yrs computing: Mean: 3.8 SD 2.4
HIV/AIDS
Flatley-Brennan, 1998^13^ | Received brochure | Mean, 34 SD, 10.8 | White non-Hispanic, (58) | NS | Mean, 14 SD, 2.7 | NR | | Living Alone: mean, 27
Flatley-Brennan, 1998^13^ | Received computer intervention | Mean, 33 SD, 7.3 | White non-Hispanic, (64) | NS | Mean, 13 SD, 2.6 | NR | | Living Alone: mean, 29
Gustafson, 1994^14^ | Control | NR | NR | NR | NR | NR | NR | | HIV-infected people
Gustafson, 1994^14^ | CHESS | NR | NR | NR | NR | NR | NR | | HIV-infected people
Menopause HRT
Rostom, 2002^15^ | Audio booklet | Mean, 53.8 SD, 8.13 | NS | NS | 8–12 yr, 7 (26.9) 12–16y r, 19(73.1) | NR | | | Currently not using HRT: 13, (50.0) Menses: 7, (26.9) Contemplating the decision: 6, 2(3.1) Strongly leaning: 18, (69.2)
Rostom, 2002^15^ | Interactive computerized DA | Mean, 50.6 SD, 7.67 | NS | NS | 8–12yr, 6 (24) 12–16 yr, 19 (76) | NR | | | Currently not using HRT: 19 (76.0) Menses: 16 (64) Contemplating the decision: 8, (32) Strongly leaning: 16 (64.0)
Schapira, 2007^16^ | Printed pamphlet | Mean, 57.8 SD, 7.5 | White non-Hispanic, 64 (73) Black non-Hispanic, 22(25) AIAN, 2 (2) | USD <19,999, 25 (28) 20,000–34,999, 32 (36) 35,000–49999, 17 (19) 50,000–74,999, 11 (13) 75,000+, 3 (3) | NS | NR | | | NS
Schapira, 2007^16^ | Computer-based decision aid | Mean, 57.8 SD, 7.2 | White non-Hispanic, 64 (72) Black non-Hispanic, 24 (27) AIAN, 1(1) | USD <19,999, 31 (35) 20,000–34,999, 22 (25) 35,000–49999, 19 (21) 50,000–74,999, 11 (12) 75,000+, 6 (7) | NS | NR | | | NS
Preventing falls in the elderly
Yardley, 2007^17^ | Control | NS | NS | NS | NS | NR | M, 42 (31) F, 94 (69) | | Self-rated balance: good 13 (9.5) quite good 32 (23.5) have some problems 91 (67) health condition (co morbidity): unsteadiness 97(71) poor vision 34 (25) take >=4 meds 60 (44) take <4 meds38 (28)
Yardley, 2007^17^ | Tailored | NS | NS | NS | NS | NR | M, 54 (37) F, 90 (63) | | Self-rated balance: good, 11 (8) quite good 38 (26) have some problems 95 (66) health condition (co morbidity): unsteadiness 106(74) poor vision 43(30) take >=4 meds 51 (35) take <4 meds52 (36)
Use of contraception
Chewning, 199^18^ | Standard information | NS | NS | NS | NS | NR | | | NS
Chewning, 199^18^ | Computerized decision | NS | NS | NS | NS | NR | | | NS

NR= Not Reported, NS= Not Significant SD= Standard Deviation, SES= Socioeconomic Status, Yr= year, API = Asian, Pacific Islander, AIAN = American Indian/Alaska Native, CVD = Cardiovascular Disease, F = female, M = Male

Reference List

1 Kukafka R, Lussier YA, Eng P, Patel VL, Cimino JJ. Web-based tailoring and its effect on self-efficacy: results from the MI-HEART randomized controlled trial. Proc AMIA Symp 2002; 410–4.

2 Simkins CV, Wenzloff NJ. Evaluation of a computerized reminder system in the enhancement of patient medication refill compliance. Drug Intell Clin Pharm 1986; 20(10):799–802.

3 Lorig KR, Ritter PL, Laurent DD, Plant K. The internet-based arthritis self-management program: a one-year randomized trial for patients with arthritis or fibromyalgia. Arthritis Rheum 2008; 59(7):1009–17.

4 Buhrman M, Faltenhag S, Strom L, Andersson G. Controlled trial of Internet-based treatment with telephone support for chronic back pain. Pain 2004; 111(3):368–77.

5 Oenema A, Brug J, Dijkstra A, de Weerdt I, de Vries H. Efficacy and use of an internet-delivered computer-tailored lifestyle intervention, targeting saturated fat intake, physical activity and smoking cessation: a randomized controlled trial. Ann Behav Med 2008; 35(2):125–35.

6 Jones R, Pearson J, McGregor S et al. Randomised trial of personalised computer based information for cancer patients. BMJ 1999; 319(7219):1241–7.

7 Campbell E, Peterkin D, Abbott R, Rogers J. Encouraging underscreened women to have cervical cancer screening: the effectiveness of a computer strategy. Prev Med 1997; 26(6):801–7.

8 Frosch DL, Bhatnagar V, Tally S, Hamori CJ, Kaplan RM. Internet patient decision support: a randomized controlled trial comparing alternative approaches for men considering prostate cancer screening. Arch Intern Med 2008; 168(4):363–9.

9 Brennan PF, Moore SM, Smyth KA. The effects of a special computer network on caregivers of persons with Alzheimer's disease. Nurs Res 1995; 44(3):166–72.

10 Harari D, Iliffe S, Kharicha K et al. Promotion of health in older people: a randomised controlled trial of health risk appraisal in British general practice. Age Ageing 2008; 37(5):565–71.

11 Paperny DM, Aono JY, Lehman RM, Hammar SL, Risser J. Computer-assisted detection and intervention in adolescent high-risk health behaviors. 1990; 116(3):456–62.

12 Devineni T, Blanchard EB. A randomized controlled trial of an internet-based treatment for chronic headache. Behav Res Ther 2005; 43(3):277–92.

13 Flatley-Brennan P. Computer network home care demonstration: a randomized trial in persons living with AIDS. Comput Biol Med 1998; 28(5):489–508.

14 Gustafson DH, Hawkins RP, Boberg EW, Bricker E, Pingree S, Chan CL. The use and impact of a computer-based support system for people living with AIDS and HIV infection. 1994; 604–8.

15 Rostom A, O'Connor A, Tugwell P, Wells G. A randomized trial of a computerized versus an audio-booklet decision aid for women considering post-menopausal hormone replacement therapy. Patient Educ Couns 2002; 46(1):67–74.

16 Schapira MM, Gilligan MA, McAuliffe T, Garmon G, Carnes M, Nattinger AB. Decision-making at menopause: a randomized controlled trial of a computer-based hormone therapy decision-aid. Patient Educ Couns 2007; 67(1–2):100–7.

17 Yardley L, Nyman SR. Internet provision of tailored advice on falls prevention activities for older people: a randomized controlled evaluation. Health Promot Int 2007; 22(2):122–8.

18 Chewning B, Mosena P, Wilson D et al. Evaluation of a computerized contraceptive decision aid for adolescent patients. Patient Educ Couns 1999; 38(3):227–39.

Evidence Table 31

Outcomes in studies addressing the impact of CHI applications on intermediate outcomes in miscellaneous conditions of interest

Author, year | Outcomes | Control Intervention | n | Measure at BL | Measure at time point 2 | Measure at time point 3 | Measure at time point 4 | Measure at final time point | Ratios at time points | Significance
CVD
Kukafka, 2002^1^ | Symptoms | Control | 17 | Self-efficacy scores | | | | | | BL, time point 2, <.05 Final time point,
Kukafka, 2002^1^ | Symptoms | Non-Tailored | 13 | Self-efficacy scores
Kukafka, 2002^1^ | Symptoms | Tailored | 17 | Self-efficacy scores | | | | | | BL, time point 3, <.001
Kukafka, 2002^1^ | Action | Control | 32 | Self-efficacy scores | 1 month | 3 month | | | | BL, time point 2, <.05 final time point,
Kukafka, 2002^1^ | Action | Non-tailored | 31 | self-efficacy scores | 1 month | 3 month
Kukafka, 2002^1^ | Action | Tailored | 31 | self-efficacy scores | 1 month | 3 month | | | | BL, time point 2, <.05 time point 3, <.05
Kukafka, 2002^1^ | Cognitive | Control | | Self-efficacy scores | 1 month | 3 month
Kukafka, 2002^1^ | Cognitive | Non-Tailored | | Self-efficacy scores | 1 month | 3 month
Kukafka, 2002^1^ | Cognitive | Tailored | | Self-efficacy scores | 1 month | 3 month | | | | BL, time point 2, <.05 time point 3, <.001 time point 4, final time point,
Simkins, 1986^2^ | Medication refill compliance | Control | 104 | Compliant months | | | | Month 3: mean, 0.58 SD, 0.5
Simkins, 1986^2^ | Medication refill compliance | Group 2 received reminder by postcard | 101 | Compliant months | | | | Month 3: mean, 0.65 SD, 0.52
Simkins, 1986^2^ | Medication refill compliance | Group 3 received reminder by calling | 69 | Compliant months | | | | Month 3 mean, 0.64 SD, 0.46
Simkins, 1986^2^ | Medication refill non-compliance | Control | 104 | non-compliant months | Month 1 | | | Month 3 mean, 0.43 SD, 0.5
Simkins, 1986^2^ | Medication refill non-compliance | Group 2 received reminder by postcard | 101 | Non-compliant months | Month 1 | | | Month 3 mean, 0.35 SD, 0.52
Simkins, 1986^2^ | Medication refill non-compliance | Group 3 received reminder by calling | 69 | Non-compliant months | Month 1 | | | Month 3 mean, 0.36 SD, 0.46
Arthritis
Lorig, 2008^3^ | Health distress | Control | 344 | Mean, 2.37 SD, 1.19 | 6months | | | 1year: mean, 2.25 SD, 1.19
Lorig, 2008^3^ | Health distress | Online intervention | 307 | Mean, 2.41 SD, 1.2 | 6months | | | 1year: mean, 2 SD, 1.18
Lorig, 2008^3^ | Activity limitation | Control | 344 | Mean, 3.22 SD, 0.903 | 6months | | | 1year mean, 3.29 SD, 0.885
Lorig, 2008^3^ | Activity limitation | Online intervention | 307 | Mean, 3.17 SD, 0.973 | 6months | | | 1year mean, 3.09 SD, 0.962
Lorig, 2008^3^ | Self reported global health | Control | 344 | Mean, 0.569 SD, 0.446 | 6months | | | 1year mean, 0.573 SD, 0.457
Lorig, 2008^3^ | Self reported global health | Online intervention | 307 | Mean, 0.547 SD, 0.401 | 6months | | | 1year mean, 0.514 SD, 0.445
Lorig, 2008^3^ | Pain | Control | 344 | Mean, 6.37 SD, 2.22 | 6months | | | 1year mean, 6.1 SD, 2.35
Lorig, 2008^3^ | Pain | Online intervention | 307 | | 6months | | | 1year mean, 5.77 SD, 2.53
Lorig, 2008^3^ | Self efficacy | Control | 344 | Mean, 4.96 SD, 1.98 | 6months | | | 1year: mean, 5.34 SD, 2.06
Lorig, 2008^3^ | Self efficacy | Online intervention | 307 | Mean, 5.08 SD, 2.13 | 6months | | | 1year: mean, 5.89 SD, 2.09
Back pain
Buhrman, 2004^4^ | CSQ-Diverting attention | Control | 29 | Mean, 12.3 SD, 7.4 | | | | 2 months: mean, 11.9 SD, 6.9
Buhrman, 2004^4^ | CSQ-Diverting attention | Cognitive behavior intervention | 22 | Mean, 11.6 SD, 5.7 | | | | 2 months: mean, 12.3 SD, 5.2
Buhrman, 2004^4^ | CSQ-Reinterpret pain sensations | Control | 29 | Mean, 5.4 SD, 6.5 | | | | 2 months mean, 4.6 SD, 5.9
Buhrman, 2004^4^ | CSQ-Reinterpret pain sensations | Cognitive behavior intervention | 22 | Mean, 3.6 SD, 3.5 | | | | 2 months mean, 4.4 SD, 3.6
Buhrman, 2004^4^ | CSQ-Coping self-statement | Control | | Mean, 18.3 SD, 6.6 | | | | 2 months mean, 17.3 SD, 6.7
Buhrman, 2004^4^ | CSQ-Coping self-statement | Cognitive behavior intervention | | Mean, 18.4 SD, 6.5 | | | | 2 months mean, 19.1 SD, 5.8
Buhrman, 2004^4^ | CSQ-Ignore pain sensations | Control | 29 | Mean, 13.5 SD, 6.6 | | | | 2 months mean, 12.9 SD, 6.5
Buhrman, 2004^4^ | CSQ-Ignore pain sensations | Cognitive behavior intervention | 22 | | | | | 2 months mean, 13.7 SD, 7
Buhrman, 2004^4^ | CSQ-Praying or hoping | Control | 29 | Mean, 10.4 SD, 6.7 | | | | 2 months: mean, 8.5 SD, 6
Buhrman, 2004^4^ | CSQ-Praying or hoping | Cognitive behavior intervention | 22 | Mean, 12 SD, 6.9 | | | | 2 months: mean, 9.8 SD, 5.1
Buhrman, 2004^4^ | CSQ-Catastrophizing | Control | 29 | Mean, 13.7 SD, 6.9 | | | | 2 months mean, 12.3 SD, 7.2
Buhrman, 2004^4^ | CSQ-Catastrophizing | Cognitive behavior intervention | 22 | Mean, 13.6 SD, 7.7 | | | | 2 months mean, 8.6 SD, 5.2
Buhrman, 2004^4^ | CSQ-Increase activity level | Control | 22 | Mean, 17.3 SD, 6.1 | | | | 2 months mean, 16.9 SD, 6.3
Buhrman, 2004^4^ | CSQ-Increase activity level | Cognitive behavior intervention | 22 | Mean, 14.4 SD, 5 | | | | 2 months mean, 14.8 SD, 5.6
Buhrman, 2004^4^ | CSQ-Control over pain | Control | 29 | Mean, 2.9 SD, 1.1 | | | | 2 months: mean, 2.9 SD, 1
Buhrman, 2004^4^ | CSQ-Control over pain | Cognitive behavior intervention | 22 | Mean, 2.8 SD, 1 | | | | 2 months: mean, 3.9 SD, 0.7
Behavioral risk factors
Oenema, 2008^5^ | Self-rated saturated fat intake | Control | 930 | Mean, −0.16 SD, 0.82 | | | | one month: mean, −0.19 SD, 0.82
Oenema, 2008^5^ | Self-rated saturated fat intake | Internet group | 887 | Mean, −0.19 SD, 0.78 | | | | One month: mean, −0.18 SD, 0.79
Oenema, 2008^5^ | Self rated PA level | Control | 890 | Mean, −0.29 SD, 0.92 | | | | One month mean, −0.3 SD, 0.93
Oenema, 2008^5^ | Self rated PA level | Internet group | 827 | Mean, −0.31 SD, 0.91 | | | | One month mean, −0.29 SD, 0.85
Breast cervical prostate and laryngeal cancer
Jones, 1999^6^ | Satisfaction Score >2 (n (%)) | Booklet (control) | 150 | | | | | 58(40)
Jones, 1999^6^ | Satisfaction Score >2 (n (%)) | Personal computer information | 156 | | | | | 68(46)
Jones, 1999^6^ | Satisfaction Score >2(95% CI of percentage | Booklet (control) | 150 | | | | | 32 to 48
Jones, 1999^6^ | Satisfaction Score >2(95% CI of percentage | Personal computer information | 156 | | | | | 38 to 54
Jones, 1999^6^ | Prefer computer to 10 minute consultation with professional | Booklet (control) | 150 | | | | | 12/122(10)
Jones, 1999^6^ | Prefer computer to 10 minute consultation with professional | Personal computer information | 156 | | | | | 38/131(29)
Cervical cancer
Campbell, 1997^7^ | Pap smear within 6 months in women who were under screened by Path report 18–49 years | Control | 32 | | | | | 6 months (24.6), 95% CI
Campbell, 1997^7^ | Pap smear within 6 months in women who were under screened by Path report 18–49 years | Experimental | 56 | | | | | 6 months (37.8), 95% CI | | NS
Campbell, 1997^7^ | Pap smear within 6 months in women who were under screened by Self report 18–49 years | Control | 44 | | | | | 6 months
Campbell, 1997^7^ | Pap smear within 6 months in women who were under screened by Self report 18–49 years | Intervention | 52 | | | | | 6 months | | NS
Campbell, 1997^7^ | Pap smear within 6 months in women who were under screened by Path report 50–70 years | Control | 41 | | | | | 6 months
Campbell, 1997^7^ | Pap smear within 6 months in women who were under screened by Path report 50–70 years | Intervention | 38 | | | | | 6 months | | NS (0.09)
Campbell, 1997^7^ | Pap smear within 6 months in women who were under screened by Self report 50–70 years | Control | 21 | | | | | 6 months
Campbell, 1997^7^ | Pap smear within 6 months in women who were under screened by Self report 50–70 years | Intervention | 22 | | | | | 6 months | | 0.026
Cancer, Prostate
Forsch, 2008^8^ | Total knowledge scores(completer cases only), mean (SE) | Traditional decision aid | 155 | | | | | Posttest: mean, 8.65 SD, 0.18
Forsch, 2008^8^ | Total knowledge scores(completer cases only), mean (SE) | Chronic disease trajectory model | 153 | | | | | Posttest: mean, 8.03 SD, 0.18
Forsch, 2008^8^ | Total knowledge scores(completer cases only), mean (SE) | Combined | 152 | | | | | Posttest: mean, 8.03 SD, 0.18
Caregiver decision making
Brennan, 1995^9^ | Decision confidence | Control | 49 | Likert scale, 14 items, 5 choices mean, 54.65 SD, 7.3 | | | | 12 months: mean, 54.7 SD, 6.1
Brennan, 1995^9^ | Decision confidence | Experimental | 47 | Likert scale 14 items, 5 choices mean, 51.9 SD, 6 | | | | 12 months: mean, 56.8 SD, 7 | | <.01
Brennan, 1995^9^ | Improved decision making skill | Control | 49 | Number of alternatives caregiver considers to solve a problem: mean, 2.51 SD, 0.91 | | | | 12 months mean, 2.37 SD, 78
Brennan, 1995^9^ | Improved decision making skill | Experimental | 47 | Number of alternatives caregiver considers to solve a problem: mean, 2.53 SD, 0.78 | | | | 12 months mean, 2.4 SD, 0.61 | | 0.2
Brennan, 1995^9^ | Isolation | Control | 49 | Score on Instrumental and Expressive Support Scale (IESS) mean, 62.7 SD, 15.5 | | | | 12 months mean, 62.6 SD, 16
Brennan, 1995^9^ | Isolation | Experimental | 47 | Mean, 63.4 SD, 16.6 | | | | 12 months mean, 65 SD, 17.4 | | 0.51
Change in health behavior
Harari, 2008^10^ | Self-reported health behavior | Control | 1066 | | | | | 12 months:(84)
Harari, 2008^10^ | Self-reported health behavior | HRA-O intervention group | 940 | | | | | 12 months (76)
Harari, 2008^10^ | Preventative care uptake | Control | 1066 | | | | | 12 months (84)
Harari, 2008^10^ | Preventative care uptake | HRA-O intervention group | 940 | | | | | 12 months (76)
Paperny, 1990^11^ | High cigarette use | Control | 10
Paperny, 1990^11^ | High cigarette use | Intervention group 1 | 25 | | | | | | | P=<0.01
Paperny, 1990^11^ | | Intervention group 2 | 25 | | | | | | | P=<0.03
Paperny, 1990^11^ | Frequent marijuana use (weekly) | Control | 8
Paperny, 1990^11^ | Frequent marijuana use (weekly) | Intervention group 1 | 19 | | | | | | | P=<0.04
Paperny, 1990^11^ | Frequent marijuana use (weekly) | Intervention group 2 | 22 | | | | | | | P=<0.03
Paperny, 1990^11^ | High alcohol use (weekly) | Control | 13
Paperny, 1990^11^ | High alcohol use (weekly) | Intervention group 1 | 28 | | | | | | | P=<0.02
Paperny, 1990^11^ | High alcohol use (weekly) | Intervention group 2 | 28 | | | | | | | NS
Paperny, 1990^11^ | Problems at home with parents, family | Control | 24
Paperny, 1990^11^ | Problems at home with parents, family | Intervention group 1 | 70 | | | | | | | P=<0.001
Paperny, 1990^11^ | Problems at home with parents, family | Intervention group 2 | 72 | | | | | | | P=<0,001
Paperny, 1990^11^ | Often sad, upset or unhappy | Control | 34
Paperny, 1990^11^ | Often sad, upset or unhappy | Intervention group 1 | 69 | | | | | | | P=<0.001
Paperny, 1990^11^ | Often sad, upset or unhappy | Intervention group 2 | 66 | | | | | | | P=<0,007
Paperny, 1990^11^ | Feeling sad or down lately | Control | 45
Paperny, 1990^11^ | Feeling sad or down lately | Intervention group 1 | 67 | | | | | | | P=<0.04
Paperny, 1990^11^ | Feeling sad or down lately | Intervention group 2 | 63 | | | | | | | NS
Paperny, 1990^11^ | Would like contraceptive information | Control | 27
Paperny, 1990^11^ | Would like contraceptive information | Intervention group 1 | 74 | | | | | | | P=<0.001
Paperny, 1990^11^ | Would like contraceptive information | Intervention group 2 | 66 | | | | | | | P=<0.001
Paperny, 1990^11^ | Has a lover now | Control | 56
Paperny, 1990^11^ | Has a lover now | Intervention group 1 | 82 | | | | | | | P=<0.03
Paperny, 1990^11^ | Has a lover now | Intervention group 2 | 82 | | | | | | | NS
Paperny, 1990^11^ | Had sexual intercourse | Control | 56
Paperny, 1990^11^ | Had sexual intercourse | Intervention group 1 | 75 | | | | | | | NS
Paperny, 1990^11^ | Had sexual intercourse | Intervention group 2 | 75 | | | | | | | NS
Paperny, 1990^11^ | Taking medications | Control | 50
Paperny, 1990^11^ | Taking medications | Intervention group 1 | 61 | | | | | | | NS
Paperny, 1990^11^ | Taking medications | Intervention group 2 | 62 | | | | | | | NS
Headache
Devineni, 2005^12^ | Headache symptom questionnaire | Control | 47 | Mean, 35.5 SD, 20.9 | | | | 2 months mean, 31.7 SD, 22.4
Devineni, 2005^12^ | Headache symptom questionnaire | Intervention | 39 | Mean, 33.8 SD, 19.3 | | | | 2 months mean, 20.3 SD, 15.9
Devineni, 2005^12^ | Headache disability inventory | Control | 39 | Mean, 54.2 SD, 20.5 | | | | 2 months mean, 49.6 SD, 23.1
Devineni, 2005^12^ | Headache disability inventory | Intervention | 39 | Mean, 52.9 SD, 18.8 | | | | 2 months mean, 38 SD, 19.5
Devineni, 2005^12^ | CES-D (depression scale) | | 47 | Mean, 13.9 SD, 9.5 | | | | 2 months mean, 14.3 SD, 12.1
Devineni, 2005^12^ | Trait-anxiety scale | Control | 39 | Mean, 25.6 SD, 15.9 | | | | 2 months mean, 20.8 SD, 17.2
Devineni, 2005^12^ | Trait-anxiety scale | Intervention | 39 | | | | | 2 months mean, 18.4 SD, 15.7
HIV/AIDS
Flatley-Brennan, 1998^13^ | Improved decision making confidence | Control | 26 | Mean score mean, 52.8 SD, 6 | | | | Post-intervention: mean, 56.47 SD, 4.2 | | BL, 0.05 time point 2, final time point, 0.05
Flatley-Brennan, 1998^13^ | Improved decision making confidence | Computer link | 31 | Mean score mean, 54.35 SD, 5.9 | | | | Post-intervention: mean, 51.45 SD, 6.9 | | BL, 0.05 time point 2, final time point, 0.05
Flatley-Brennan, 1998^13^ | Improved decision making skill | Control | 26 | Mean score: mean, 4.73 SD, 1.4 | | | | Post-intervention mean, 5.47 SD, 1.3 | | BL, 0.05 time point 2, final time point, 0.05
Flatley-Brennan, 1998^13^ | Improved decision making skill | Computer link | 31 | Mean Score: mean, 4.58 SD, 5.4 | | | | Post-intervention mean, 5.4 SD, 1.5 | | BL, 0.05 time point 2, final time point, 0.05
Flatley-Brennan, 1998^13^ | Reduced social isolation | Control | 26 | Mean score mean, 67.05 SD, 17 | | | | Post-intervention mean, 68 SD, 16.8 | | BL, 0.05 time point 2, final time point, 0.05
Flatley-Brennan, 1998^13^ | Reduced social isolation | Computer Link | 31 | Mean score mean, 63.5 SD, 14.4 | | | | Post-intervention mean, 66.08 SD, 13.68 | | BL, 0.05 time point 2, final time point, 0.05
Flatley-Brennan, 1998^13^ | Differential decline in health status | Control | 26 | Mean score mean, 13.8 SD, 4.93 | | | | Post-intervention mean, 13.65 SD, 1.3 | | BL, 0.05 final time point, 0.05
Flatley-Brennan, 1998^13^ | Differential decline in health status | Computer link | 31 | | | | | Post-intervention mean, 13 SD, 1.7 | RR or OR time point 2, 0.05 | BL, 0.05 time point 2, No improvement over control
Gustafson, 1994^14^ | Average Quality of life (%) | Control | 28 | | | | | (65)
Gustafson, 1994^14^ | Average Quality of life (%) | CHESS | 30 | | | | | (68)
Gustafson, 1994^14^ | Hospital cost ($/person/Month) | Control | 97 | | | | | Cost went up $457
Gustafson, 1994^14^ | Hospital cost ($/person/Month) | CHESS | 107 | | | | | Cost went down $148
Menopause HRT
Rostom, 2002^15^ | Realistic expectations | Control | 26 | Final score: difference in Mean scores; baseline and point 4 score: mean score mean, 37.2 SD, 25.5 | | | | Difference in posttest score-baseline score: mean, 52.7 SD, 37.5 | | p=0.015, t=2.530, mean deviation =0.25. p=0.023, Mann-Whitney U = 205, Z = −2.282
Rostom, 2002^15^ | Realistic expectations | Computerized decision aid | 25 | Final score: difference in Mean scores; baseline and point 4 score: mean score mean, 32 SD, 30.4 | | | | Difference in posttest score-baseline score: mean, 52.7 SD, 37.5 | | p=0.015, t=2.530, mean deviation =0.25. p=0.023, Mann-Whitney U = 205, Z = −2.282
Rostom, 2002^15^ | Knowledge | Control | 26 | Final score: difference in Mean scores; baseline and point 4 score: mean score: mean, 78.7 SD, 16.7 | | | Post-intervention questionnaire mean, 87.1 SD, 11.8 | Difference in posttest score-baseline score mean, 8.4 SD, 13.3 | | p= 0.019, t = 2.423, mean deviation = 0.0906. p=0.017, Mann-Whitney U = 201, Z= −2.397
Rostom, 2002^15^ | Knowledge | Computerized decision aid | 25 | Final score: difference in Mean scores; baseline and point 4 score: mean score: mean, 76.4 SD, 14.9 | | | Post-intervention questionnaire mean, 93.8 SD, 9 | Difference in posttest score-baseline score mean, 17.5 SD, 13.4 | | p= 0.019, t = 2.423, mean deviation = 0.0906. p=0.017, Mann-Whitney U = 201, Z= −2.397
Schapira, 2007^16^ | Menopause-related knowledge and health-risk expectations | Control | 86 | | | | | 3 months mean, 15.5 ; median, ; range, 14.9, 16.0;
Schapira, 2007^16^ | Menopause-related knowledge and health-risk expectations | Computer-based decision aid | 85 | | | | | 3 months mean, 15.1 ; median, ; range, 14.5, 15.7;,
Schapira, 2007^16^ | Satisfaction with decision | Control | 85 | | 3 months prior decision | | | 3 months mean, 4.37 median, range, 4.26, 4.48
Schapira, 2007^16^ | Satisfaction with decision | Computer-based decision aid | 85 | | 3 months prior decision | | | 3 months mean, 4.37 median, range, 4.26, 4.47
Schapira, 2007^16^ | Decisional conflict | Control | 85 | | 3 months prior decision | | | 3 months mean, 1.78 median, range, 1.67, 1.90
Schapira, 2007^16^ | Decisional conflict | computer-based decision aid | 85 | | 3 months prior decision | | | 3 months mean, 1.74 median, range, 1.62, 1.85
Schapira, 2007^16^ | Decisional conflict Decisional uncertainty subscale | Control | 85 | | 3 months prior decision | | | 3 months mean, 1.9 median, range, 1.75, 2.05
Schapira, 2007^16^ | Decisional conflict Decisional uncertainty subscale | Computer-based decision aid | 85 | | 3 months prior decision | | | 3 months mean, 1.88 range, 1.73, 2.03
Schapira, 2007^16^ | Decisional conflict Factors of uncertainty subscale | Control | 85 | | 3 months prior decision | | | 3 months: mean, 1.78 : range, 1.66, 1.91:
Schapira, 2007^16^ | Decisional conflict Factors of uncertainty subscale | Computer-based decision aid | 85 | | 3 months prior decision | | | 3 months: mean, 1.73 SD, 1.61, 1.86
Schapira, 2007^16^ | Decisional conflict Effective decision-making subscale | | 85 | | 3 months prior decision | | | 3 months mean, 1.70 median, range, 1.58, 1.82 SD,
Schapira, 2007^16^ | Decision to use hormone therapy | Control | 86 | | 3 months - prior decision | | | 3 months
Schapira, 2007^16^ | Decision to use hormone therapy | Computer-based decision aid | 85 | | 3 months - prior decision | | | 3 months | | 0.85
preventing falls in the elderly
Yardley, 2007^17^ | Intention to carry out the recommended activities | Control | 136 | 6 point scale | | | | Adter reviewing the intervention or control web site: mean, 4.65 SD, 0.79
Yardley, 2007^17^ | Intention to carry out the recommended activities | Tailored | 144 | 6 point scale | | | | Adter reviewing the intervention or control web site: mean, 4.86 SD, 0.61
Yardley, 2007^17^ | Personal relevance | Control | 136 | | | | | Adter reviewing the intervention or control web site mean, 4.6 SD, 0.77
Yardley, 2007^17^ | Personal relevance | Tailored | 144 | | | | | Adter reviewing the intervention or control web site mean, 4.83 SD, 0.65
Yardley, 2007^17^ | Interest | Control | 136 | | | | | Adter reviewing the intervention or control web site mean, 5.08 SD, 0.64
Yardley, 2007^17^ | Interest | Tailored | 144 | | | | | Adter reviewing the intervention or control web site mean, 5.03 SD, 0.61
Yardley, 2007^17^ | Suitability of the activities | Control | 136 | | | | | Adter reviewing the intervention or control web site mean, 4.8 SD, 0.79
Yardley, 2007^17^ | Suitability of the activities | Tailored | 144 | | | | | Adter reviewing the intervention or control web site mean, 4.95 SD, 0.6 | | BL, time point 2, CI −0.055, 0.009 NS
Yardley, 2007^17^ | Self-efficacy | Control | 136 | | | | | Adter reviewing the intervention or control web site: mean, 4.35 SD, 0.95
Yardley, 2007^17^ | Self-efficacy | Tailored | 144 | | | | | Adter reviewing the intervention or control web site: mean, 4.61 SD, 0.7
Yardley, 2007^17^ | Outcome expectancy | Control | 136 | | | | | Adter reviewing the intervention or control web site mean, 4.79 SD, 0.74
Yardley, 2007^17^ | Outcome expectancy | Tailored | 144 | | | | | Adter reviewing the intervention or control web site mean, 4.78 SD, 0.67
use of contraception
Chewning, 1999^18^ | OC knowledge Chicago | Control | NA | Mean, 1.95 SD, 1.13 | Initial visit mean, 2.29 SD, 1.03 | | | 1 year: mean, 3.05 SD, 1.24 | | BL, 0.709 time point 2, 0 final time point, NS
Chewning, 1999^18^ | OC knowledge Chicago | Computerized decision aid | NA | Mean, 1.89 SD, 1.07 | Initial visit mean, 3.28 SD, 1.17 | | | 1 year: mean, 3.23 SD, 1.27 | | BL, 0.709 time point 2, 0 final time point, NS
Chewning, 1999^18^ | OC knowledge Madison | Control | NA | Mean, 2.48 SD, 1.21 | Initial visit mean, 3.58 SD, 1.06 | | | 1 year mean, 3.76 SD, 1.02 | | BL, 0.813 time point 2, 0 final time point, 0.031
Chewning, 1999^18^ | OC knowledge Madison | Computerized decision aid | NA | Mean, 2.46 SD, 1.3 | Initial visit mean, 4.49 SD, 0.78 | | | 1 year mean, 3.95 SD, 0.91 | | BL, 0.813 time point 2, 0 final time point, 0.031
Chewning, 1999^18^ | OC efficacy Chicago | Control | NA | | Initial visit mean, 11.26 SD, 15.93 | | | 1 year mean, 6.38 SD, 13.45 | | BL, time point 2, 0 final time point, NS
Chewning, 1999^18^ | OC efficacy Chicago | Computerized decision aid | NA | | Initial visit mean, 4.59 SD, 9.2 | | | 1 year mean, 5.66 SD, 8.45 | | BL, time point 2, 0 final time point, NS
Chewning, 1999^18^ | OC efficacy Madison | Control | NA | | Initial visit mean, 4.8 SD, 5.58 | | | 1 year mean, 4.83 SD, 9.15 | | BL, time point 2, 0
Chewning, 1999^18^ | OC efficacy Madison | Computerized decision aid | NA | Mean, 2.09 SD, 2.2 | Initial visit | | | 1 year mean, 4 SD, 8.26 | | BL, NS time point 2,

BL = baseline, SD = standard deviation, CI = confidence interval, OC = oral contraceptive, CES-D = Center for Epidemiologic Studies Depression Scale

Reference List

1 Kukafka R, Lussier YA, Eng P, Patel VL, Cimino JJ. Web-based tailoring and its effect on self-efficacy: results from the MI-HEART randomized controlled trial. Proc AMIA Symp 2002; 410–4.

2 Simkins CV, Wenzloff NJ. Evaluation of a computerized reminder system in the enhancement of patient medication refill compliance. Drug Intell Clin Pharm 1986; 20(10):799–802.

3 Lorig KR, Ritter PL, Laurent DD, Plant K. The internet-based arthritis self-management program: a one-year randomized trial for patients with arthritis or fibromyalgia. Arthritis Rheum 2008; 59(7):1009–17.

4 Buhrman M, Faltenhag S, Strom L, Andersson G. Controlled trial of Internet-based treatment with telephone support for chronic back pain. Pain 2004; 111(3):368–77.

5 Oenema A, Brug J, Dijkstra A, de Weerdt I, de Vries H. Efficacy and use of an internet-delivered computer-tailored lifestyle intervention, targeting saturated fat intake, physical activity and smoking cessation: a randomized controlled trial. Ann Behav Med 2008; 35(2):125–35.

6 Jones R, Pearson J, McGregor S et al. Randomised trial of personalised computer based information for cancer patients. BMJ 1999; 319(7219):1241–7.

7 Campbell E, Peterkin D, Abbott R, Rogers J. Encouraging underscreened women to have cervical cancer screening: the effectiveness of a computer strategy. Prev Med 1997; 26(6):801–7.

8 Frosch DL, Bhatnagar V, Tally S, Hamori CJ, Kaplan RM. Internet patient decision support: a randomized controlled trial comparing alternative approaches for men considering prostate cancer screening. Arch Intern Med 2008; 168(4):363–9.

9 Brennan PF, Moore SM, Smyth KA. The effects of a special computer network on caregivers of persons with Alzheimer's disease. Nurs Res 1995; 44(3):166–72.

10 Harari D, Iliffe S, Kharicha K et al. Promotion of health in older people: a randomised controlled trial of health risk appraisal in British general practice. Age Ageing 2008; 37(5):565–71.

11 Paperny DM, Aono JY, Lehman RM, Hammar SL, Risser J. Computer-assisted detection and intervention in adolescent high-risk health behaviors. 1990; 116(3):456–62.

12 Devineni T, Blanchard EB. A randomized controlled trial of an internet-based treatment for chronic headache. Behav Res Ther 2005; 43(3):277–92.

13 Flatley-Brennan P. Computer network home care demonstration: a randomized trial in persons living with AIDS. Comput Biol Med 1998; 28(5):489–508.

14 Gustafson DH, Hawkins RP, Boberg EW, Bricker E, Pingree S, Chan CL. The use and impact of a computer-based support system for people living with AIDS and HIV infection. 1994; 604–8.

15 Rostom A, O'Connor A, Tugwell P, Wells G. A randomized trial of a computerized versus an audio-booklet decision aid for women considering post-menopausal hormone replacement therapy. Patient Educ Couns 2002; 46(1):67–74.

16 Schapira MM, Gilligan MA, McAuliffe T, Garmon G, Carnes M, Nattinger AB. Decision-making at menopause: a randomized controlled trial of a computer-based hormone therapy decision-aid. Patient Educ Couns 2007; 67(1–2):100–7.

17 Yardley L, Nyman SR. Internet provision of tailored advice on falls prevention activities for older people: a randomized controlled evaluation. Health Promot Int 2007; 22(2):122–8.

18 Chewning B, Mosena P, Wilson D et al. Evaluation of a computerized contraceptive decision aid for adolescent patients. Patient Educ Couns 1999; 38(3):227–39.

Evidence table 32

Description of RCTs addressing the impact of CHI applications on relationship-centered outcomes

Author, year | Consumer under study | CHI Application type | Location | Year data collected/ duration of intervention | Inclusion criteria | Exclusion criteria | Control | Intervention | Jadad score
Breast cancer
Green, 2005^1^ | Individuals interested in their own health care | Personalized health risk assessment tool | Clinician office | Between May 2000 and September 2002 | ≥18 yr, Female, Read, write and speak English, Scheduled a genetic counseling appt to evaluate personal and/or family history of breast cancer, Able to give informed consent | Previously underwent genetic counseling, Testing for inherited breast cancer susceptibility | Counseling without computer intervention | Counseling with computer intervention | −1
Gustafson, 2008^2^ | Individuals interested in their own health care | Interactive consumer website | Home/ residence | Between April 1995 and May 1997 | <60 yr, Breast cancer patients, Within 6 months of diagnosis, Not homeless, Not active illegal drug users | | Allocated standard intervention | Received CHESS intervention | 2
Gustafson, 2001^3^ | Individuals interested in their own health care | Interactive consumer website | Home/ residence | Between April 1995 and May 1997 | <60 yr, Breast cancer patients, Within 6 months of diagnosis, Not homeless, Not active illegal drug users | | Allocated standard intervention | Received CHESS intervention | 1
Maslin, 1998^4^ | Individuals interested in their own health care | Interactive computerized video system | Clinician office | NS | Non metastatic breast cancer | Advanced breast cancer, Metastatic disease, Sensory impairment, do not understand English | Standard care | Interactive computerized video system | −1
Caregiver decision making
Brennan, 1995^5^ | Caregivers of persons with Alzheimer's Disease | Interactive consumer website | Home/ residence | NS | Primary responsibility as a family caregiver for a person with Alzheimer's disease living at home, Has a local telephone exchange, The ability to read and write English | | Comparison group | Computer link program | 2
HIV/AIDS
Flatley-Brennan, 1998^6^ | Individuals interested in their own health care | Interactive consumer website | Home/ residence | NS | HIV infected, Ability to read and type English, Home telephone line | | Received brochure | Received computer intervention | 0
Arthritis
Sciamanna, 2005^7^ | Individuals interested in their own health care | Interactive consumer website | Home/ residence | NS | Had knee joint symptoms for at least the past three months, Saw a doctor for knee symptoms, Has the diagnosis of osteoarthritis | Patient did not report having knee joint symptoms for at least the past three months, Patient did not report having been seen by a doctor for the knee symptoms, Does not have the diagnosis of osteoarthritis | Completed questionnaire before intervention | Completed questionnaire after intervention | −1
Vaginal or c-section delivery
Montgomery, 2007^8^ | Individuals interested in their own health care | Decision analysis tool re caesarean delivery after having had a caesarean delivery | Home/ residence Clinician office | 2004 (may) to 2006 (august) | Pregnant, one previous lower segment caesarean section, no current obstetric problems, delivery expected at >= 37 weeks | Limited ability to speak or understand English | Usual care | Information program and website Decision-Analysis Program | 3

NS = Not specified, Yr = year, CHESS = Comprehensive Health Enhancement Support System

Reference List

1 Green MJ, Peterson SK, Baker MW et al. Use of an educational computer program before genetic counseling for breast cancer susceptibility: effects on duration and content of counseling sessions. Genet Med 2005; 7(4):221–9.

2 Gustafson DH, Hawkins R, Mctavish F et al. Internet-based interactive support for cancer patients: Are integrated systems better? 2008; 58(2):238–57.

3 Gustafson DH, Hawkins R, Pingree S et al. Effect of computer support on younger women with breast cancer. J Gen Intern Med 2001; 16(7):435–45.

4 Maslin AM, Baum M, Walker JS, A'Hern R, Prouse A. Using an interactive video disk in breast cancer patient support. Nurs Times 1998; 94(44):52–5.

5 Brennan PF, Moore SM, Smyth KA. The effects of a special computer network on caregivers of persons with Alzheimer's disease. Nurs Res 1995; 44(3):166–72.

6 Flatley-Brennan P. Computer network home care demonstration: a randomized trial in persons living with AIDS. Comput Biol Med 1998; 28(5):489–508.

7 Sciamanna CN, Harrold LR, Manocchia M, Walker NJ, Mui S. The effect of web-based, personalized, osteoarthritis quality improvement feedback on patient satisfaction with osteoarthritis care. Am J Med Qual 2005; 20(3):127–37.

8 Montgomery AA, Emmett CL, Fahey T et al. Two decision aids for mode of delivery among women with previous caesarean section: randomised controlled trial. BMJ 2007; 334(7607):1305.

Evidence Table 33

Description of consumer characteristics in RCTs addressing KQ 1c (impact of CHI applications on relationship-centered outcomes)

Author,year | Control Intervention | Age | Race, n(%) | Income | Education, n(%) | SES | Gender, n(%) | Marital Status | Other
Breast cancer
Green, 2005^1^ | Counseling without computer intervention | Mean, 44 range, 24–71 | White non-Hispanic, 100(95) | NS | College grad, 53 (50) | NR | | | Religion Catholic, 27 (26) Protestant , 52 (50) Jewish, 7 (7) Computer use at work Often or sometimes, 71 (72) Computer use, personal affairs Often or sometimes, 63 (61) Very Confident computer skills. 39 (37)
Green, 2005^1^ | Counseling & Interactive computer program | Mean, 45 range, 23–77 | White non-Hispanic, 100(95) | NS | College grad, 65 (62) | NR | | | Religion Catholic, 38 (37) Protestant, 45 (44) Jewish, 7 (7) Computer use, work Often or sometimes, 83 (82) Computer use, personal Often or sometimes, 68 (65) Very Confident computer skills, 44 (42)
Gustafson, 2008^2^ | Usual Care with books | | NS | NS | NS | NR | | | NS
Gustafson, 2008^2^ | CHESS | | NS | NS | NS | NR | | | NS
Gustafson, 2001^3^ | Allocated standard intervention | Mean, 44.4 SD, 7.1 | White non-Hispanic, (72) | USD >40,000, (50.8) | Bachelor’s degree, (40.2) | NR | | Living with Partner, (72.6) | Insurance Private Insurance, (84.7)
Gustafson, 2001^3^ | Received CHESS intervention, a home based computer system | Mean, 44.3 SD, 6.6 | White non-Hispanic, (76) | USD 40,000, (58.1) | Bachelor’s degree, (45.8) | NR | | Living with Partner, (71.9) | Insurance Private Insurance, (86)
Maslin, 1998^4^ | Standard care | Mean, 52.1 | NS | NS | NS | NR | | | NS
Maslin, 1998^4^ | Interactive Video Disk for shared decision making | | NS | NS | NS | NR | | | NS
Caregiver decision making
Brennan, 1995^5^ | Comparison group | Mean, 64 | White non-Hispanic, (72) | NS | (86) | NR | F, (67)
Brennan, 1995^5^ | Computer Link | | NS | NS | NS | NR | | | NS
HIV/AIDS
Flatley-Brennan, 1998^6^ | Received brochure | Mean, 34 SD, 10.8 | White non-Hispanic, (58) | NS | mean, 14 SD, 2.7 | NR | | Living Alone
Flatley-Brennan, 1998^6^ | Received Computer Link | mean, 33 SD, 7.3 | White non-Hispanic, (64) | NS | mean, 13 SD, 2.6 | NR | | Living Alone
Arthritis
Sciamanna, 2005^7^ | Completed questionnaire before intervention | Mean, 49.3 | White non-Hispanic, 50 (87.7) black non-Hispanic, 4 (7) Latino/Hispanic, 1 (1.8) API, 0, (0) AIAN, 1, (1.8) | NS | 14 (24.6) | NR | F, 41 (71.9) M, 16 (28.9)
Sciamanna, 2005^7^ | Patient satisfaction survey administered after participating in the web-based intervention | Mean, 46.6 | White non-Hispanic, 55, (85.9) Black non-Hispanic, 4 (6.3) Latino/Hispanic, 3 (4.7) AIAN, 2 (3.1) | NS | 17 (26.6) | NR | F, 52 (81.3) M, 12 (18.7)
Vaginal or c-section delivery
Montgomery, 2007^8^ | Usual Care | Mean, 32.4 SD, 4.6 | NS | Pound <20, 42 (18) 20-30, 53 (23) 30–40, 51 (22) 40–50, 43 (18) >50, 46 (20) | Highest Educational Qualification None, 12 (5) GCSE, 99 (40) A level, 42 (17) Degree,92 (38) | NR | | | Previous caesarean section Elective, 62(25) Emergency, 184(75) Decisional conflict scale (total) SD, 17.1 Preferred mode of delivery Vaginal, 111(45) Elective caesarean, 53(21) Unsure, 83(34)
Montgomery, 2007^8^ | Computerized Educational Information | Mean, 32.8 SD, 4.7 | NS | Pounds <20, 44 (19) 20–30, 57 (24) 30–40, 46 (19) 40–50, 37 (16) >50, 52 (22) | Highest Educational Qualification None, 10(4) GCSE, 92(37) A level, 47(19) Degree, 97(39) | NR | | | Previous caesarean section elective, 55(22) emergency, 192(78) Decisional conflict scale (total) mean, 40.2 SD, 16.6 Preferred mode of delivery Vaginal, 112(45) Elective caesarean, 52(21) Unsure, 86(34)
Montgomery, 2007^8^ | Decision analysis program | Mean, 32.5 SD, 4.8 | NS | Pounds <20, 48 (20) 20–30, 49 (21) 30–40, 44 (19) 40–50, 46 (19) >50, 50 (21) | Highest Educational Qualification None, 7(3) GCSE, 97(40) A level (36(15) Degree, 103(42) | NR | | | Previous caesarean section Elective, 49(20) Emergency, 193(80) Decisional conflict scale (total) mean, 37.8 SD, 17.2 Preferred mode of delivery Vaginal, 111(45) Elective caesarean, 50(20) Unsure, 84(34)

NR= Not Reported, NS= Not Significant, SD= Standard Deviation, SES= Socioeconomic Status, Yr= year, AIAN = American Indian/Alaska Native, API = Asian/Pacific Islander, GCSE= General Certificate of Secondary Education

Reference List

1 Green MJ, Peterson SK, Baker MW et al. Use of an educational computer program before genetic counseling for breast cancer susceptibility: effects on duration and content of counseling sessions. Genet Med 2005; 7(4):221–9.

2 Gustafson DH, Hawkins R, Mctavish F et al. Internet-based interactive support for cancer patients: Are integrated systems better? 2008; 58(2):238–57.

3 Gustafson DH, Hawkins R, Pingree S et al. Effect of computer support on younger women with breast cancer. J Gen Intern Med 2001; 16(7):435–45.

4 Maslin AM, Baum M, Walker JS, A'Hern R, Prouse A. Using an interactive video disk in breast cancer patient support. Nurs Times 1998; 94(44):52–5.

5 Brennan PF, Moore SM, Smyth KA. The effects of a special computer network on caregivers of persons with Alzheimer's disease. Nurs Res 1995; 44(3):166–72.

6 Flatley-Brennan P. Computer network home care demonstration: a randomized trial in persons living with AIDS. Comput Biol Med 1998; 28(5):489–508.

7 Sciamanna CN, Harrold LR, Manocchia M, Walker NJ, Mui S. The effect of web-based, personalized, osteoarthritis quality improvement feedback on patient satisfaction with osteoarthritis care. Am J Med Qual 2005; 20(3):127-37.

8 Montgomery AA, Emmett CL, Fahey T et al. Two decision aids for mode of delivery among women with previous caesarean section: randomised controlled trial. BMJ 2007; 334(7607):1305.

Evidence Table 34

Outcomes in studies addressing the impact of CHI applications on relationship-centered outcomes

Author, year | Outcomes | Control Intervention | n | Measure at BL | Measure at time point 2 | Measure at time point 3 | Measure at time point 4 | Measure at final time point | ratios at time points | Significance
Breast Cancer
Green, 2005^1^ | Alter content of discussions | Control | 105 | | | | | After counseling session with genetic counselor
Green, 2005^1^ | Alter content of discussions | Counseling & Interactive computer program | 106 | | | | | After counseling session with genetic counselor:100 | | 0.03
Green, 2005^1^ | Change the way they used their time | Control | 105 | | | | | After counseling session with genetic counselor
Green, 2005^1^ | Change the way they used their time | Counseling & Interactive computer program | 106 | | | | | After counseling session with genetic counselor:100
Green, 2005^1^ | Used time more efficiently | Control | 105 | | | | | After counseling session with genetic counselor
Green, 2005^1^ | Used time more efficiently | Counseling & Interactive computer program | 106 | | | | | After counseling session with genetic counselor:100
Green, 2005^1^ | Skip material typically present | Control | 105 | | | | | After counseling session with genetic counselor
Green, 2005^1^ | Skip material typically present | Counseling & Interactive computer program | 106 | | | | | After counseling session with genetic counselor:100
Green, 2005^1^ | Effectiveness of counseling session | Control | 105 | | | | | After counseling session with genetic counselor
Green, 2005^1^ | Effectiveness of counseling session | Counseling & Interactive computer program | 106 | | | | | After counseling session with genetic counselor:100 | | Final time point, 0.81 (patients) and 0.45 (counselors)
Green, 2005^1^ | Shorter counseling sessions | Control | 105 | | | | | After counseling session with genetic counselor
Green, 2005^1^ | Shorter counseling sessions | Counseling & Interactive computer program | 106 | | | | | After counseling session with genetic counselor | | Final time point, 0.03
Gustafson, 2008^2^ | Social support | Control | 80 | Quality of life mean, 0.18 SD, 0.53 | | | | 9 month: mean, 0.11 SD, 0.45 | | BL, .058 .039 .126 Time point 2, .24 .004 .32 Final time point, .018 .021 .028
Gustafson, 2008^2^ | Social support | Internet | 75 | Quality of life mean, -0.02 SD, 0.56 | | | | 9 month: mean, 0.07 SD, 0.45 | | BL,.84 .39 .69 Time point 2, .44 .77 .53 Final time point, .33 .57 .48
Gustafson, 2008^2^ | Social support | CHESS | 80 | Quality of life mean, 0.02 SD, 0.54 | | | | 9 month: mean, 0.18 SD, 0.54 | | BL, .029 .003 .007 Time point 2, 0.47 .027 .15 Final time point, .14 .14 .16
Gustafson, 2008^2^ | Quality of life | Control | 80 | Social support: mean, 0.23 SD, 0.49 | 4 month | | | 9 month mean, 0.13 SD, 0.54
Gustafson, 2008^2^ | Quality of life | Internet | 75 | social support: mean, -0.08 SD, 0.56 | 4 month | | | 9 month mean, 0.06 SD, 0.58
Gustafson, 2008^2^ | Quality of life | CHESS | 80 | Social support: mean, 0.16 SD, 0.49 | 4 month | | | 9 month mean, 0.21 SD, 0.55
Gustafson, 2008^2^ | Health competence | Control | 80 | Health and information competence mean, 0.17SD, 0.39 | 4 month | | | 9 month mean, 0.12 SD, 0.37
Gustafson, 2008^2^ | Health competence | Internet | 75 | Health and information competence mean, -0.03SD, 0.48 | 4 month | | | 9 month mean, 0.06 SD, 0.49
Gustafson, 2008^2^ | Health competence | CHESS | 80 | Health and information competence mean, 0.12SD, 0.47 | 4 month | | | 9 month mean, 0.18 SD, 0.48
Gustafson, 2001^3^ | Information competence | Control | 125 | | 2 month mean, 65.6 | | | 5 month: mean, 65.8 | | Time point 2, 0.01
Gustafson, 2001^3^ | Information competence | Chess | 121 | | 2 month mean, 70.4 | | | 5 month: mean, 69.3 | | Time point 2, 0.01
Gustafson, 2001^3^ | Participation | Control | 125 | | 2 month mean, 74.3 | | | 5 month | | time point 2, 0.01
Gustafson, 2001^3^ | Participation | CHESS | 121 | | 2 month mean, 80.7 | | | 5 month | | Time point 2, 0.01
Gustafson, 2001^3^ | Participation | Control | 125 | | 2 month mean, 74.3 | | | 5 month | | Time point 2, 0.01
Gustafson, 2001^3^ | Participation | CHESS | 121 | | 2 month mean, 80.7 | | | 5 month | | Time point 2, 0.01
Gustafson, 2001^3^ | Confidence in doctors | Control | 125 | | 2 month mean, 77.3 | | | 5 month | | Time point 2, 0.05
Gustafson, 2001^3^ | Confidence in doctors | CHESS | 121 | mean, 83 | 2 month | RR or OR time point 3, 0.05 | | 5 month
Maslin, 1998^4^ | Anxiety and depression | Interactive Video Disk forshared decision making | 51 | Score on HAD | | | | 9 months later
Maslin, 1998^4^ | Anxiety and depression | | 51 | | | | | 9 months later
Maslin, 1998^4^ | Satisfaction with treatment decision | Control | 51 | | | | | 9 months after diagnosis
Maslin, 1998^4^ | Satisfaction with treatment decision | Interactive Video Disk forshared decision making | 51 | | | | | 9 months after diagnosis
Caregiver decision making
Brennan, 1995^5^ | Decision confidence | Control | 49 | Likert scale, 14 items, 5 choices mean, 54.65 SD, 7.3 | | | | 12 months: mean, 54.7 SD, 6.1
Brennan, 1995^5^ | Decision confidence | ComputerLink | 47 | Likert scale 14 items, 5 choices mean, 51.9 SD, 6 | | | | 12 months: mean, 56.8 SD, 7 | | <.01
Brennan, 1995^5^ | Improved decision making skill | Control | 49 | Number of alternatives caregiver considers to solve a problem: mean, 2.51 SD, 0.91 | | | | 12 months mean, 2.37 SD, 78
Brennan, 1995^5^ | Improved decision making skill | ComputerLink | 47 | Number of alternatives caregiver considers to solve a problem: mean, 2.53 SD, 0.78 | | | | 12 months mean, 2.4 SD, 0.61 | | 0.2
Brennan, 1995^5^ | Isolation | Control | 49 | Score on Instrumental and Expressive Support Scale (IESS) mean, 62.7SD, 15.5 | | | | 12 months mean, 62.6 SD, 16
Brennan, 1995^5^ | Isolation | ComputerLink | 47 | mean, 63.4SD, 16.6 | | | | 12 months mean, 65 SD, 17.4 | | 0.51
HIV/AIDS
Flatley-Brennan, 1998^6^ | Improved decision making confidence | Control | 26 | Mean score mean, 52.8 SD, 6 | | | | Post-intervention: mean, 56.47 SD, 4.2 | | BL, 0.05 time point 2, final time point, 0.05
Flatley-Brennan, 1998^6^ | Improved decision making confidence | Computer Link | 31 | Mean score mean, 54.35 SD, 5.9 | | | | Post-intervention:mean, 51.45 SD, 6.9 | | BL, 0.05 time point 2, final time point, 0.05
Flatley-Brennan, 1998^6^ | Improved decision making skill Reduced social isolation | Control | 26 | Mean score: mean, 4.73 SD, 1.4 | | | | Post-intervention mean, 5.47 SD, 1.3 | | BL, 0.05 time point 2, final time point, 0.05
Flatley-Brennan, 1998^6^ | Improved decision making skill Reduced social isolation | Computer Link | 31 | Mean Score: mean, 4.58 SD, 5.4 | | | | Post-intervention mean, 5.4 SD, 1.5 | | BL, 0.05 time point 2, final time point, 0.05
Flatley-Brennan, 1998^6^ | Improved decision making skill Reduced social isolation | Control | 26 | Mean score mean, 67.05SD, 17 | | | | Post-intervention mean, 68 SD, 16.8 | | BL, 0.05 time point 2, final time point, 0.05
Flatley-Brennan, 1998^6^ | | Computer Link | 31 | Mean score mean, 63.5SD, 14.4 | | | | Post-intervention mean, 66.08 SD, 13.68 | | BL, 0.05 time point 2, final time point, 0.05
Flatley-Brennan, 1998^6^ | Differential decline in health status | | 26 | Mean score mean, 13.8 SD, 4.93 | | | | Post-intervention mean, 13.65 SD, 1.3 | | BL, 0.05 final time point, 0.05
Flatley-Brennan, 1998^6^ | Differential decline in health status | Computer Link | 31 | | RR or OR time point 2, 0.05 | | | Post-interventionmean, 13 SD, 1.7 | | BL, 0.05 time point 2, No improvement over control
Arthritis
Sciamanna, 2005^7^ | Patient overall satisfaction score with the osteoarthritis care they are receiving | Control | 57 | | | | | One measurement only, survey before or after viewing the web-based module
Sciamanna, 2005^7^ | Patient overall satisfaction score with the osteoarthritis care they are receiving | www.myexpertdoctor.com tailored feedback on quality of received care | 64 | | | | | One measurement only, survey before or after viewing the web-based module: | | BL, No diff between control & intervention group time point 2,final time point
Vaginal or c-section delivery
Montgomery, 2007^8^ | mean (SD) on DCS at follow up | Usual Care | 201 | Total score on DCS | | | | 37 weeks gestation (DCS): mean, 27.8 SD, 14.6
Montgomery, 2007^8^ | mean (SD) on DCS at follow up | Computerized Educational Information | 201 | Total score on DCS | | | | 37 weeks gestation (DCS): mean, 22.5 SD, 13.2
Montgomery, 2007^8^ | mean (SD) on DCS at follow up | Decision analysis program | 198 | Total score on DCS | | | | 37 weeks gestation (DCS): mean, 23.6 SD, 15.1
Montgomery, 2007^8^ | Difference between groups in total score on DCS (decision v usual care) | Usual Care | 201 | Difference between groups on total score on DCS(adjusted figure | 2 weeks post delivery (satisfaction with decision) | | time point 4,OR:1.42(0.94 to 2.14) | 37 weeks gestation (DCS) mean, −4 range,−6.5 to −1.5 | | 0.22
Montgomery, 2007^8^ | Odds ratio for caesarean (elective and emergency) v vaginal, decision v usual care | Computerized Educational Information | 201 | Odds ratio for vaginal v c section (elective and emergency) decision analysis v usual care | 2 weeks post delivery (satisfaction with decision) | | | 37 weeks gestation (DCS)
Montgomery, 2007^8^ | Odds ratio for caesarean (elective and emergency) v vaginal, decision v usual care | Decision analysis program | | | 2 weeks post delivery (satisfaction with decision) | | | 37 weeks gestation (DCS)
Montgomery, 2007^8^ | Odds ratio for caesarean (elective and emergency) v vaginal, decision v usual care | Usual Care | | | 2 weeks post delivery (satisfaction with decision) | | | 37 weeks gestation (DCS)
Montgomery, 2007^8^ | Odds ratio for caesarean (elective and emergency) v vaginal, decision v usual care | Computerized Educational Information | | | 2 weeks post delivery (satisfaction with decision) | | | 37 weeks gestation (DCS)
Montgomery, 2007^8^ | Satisfaction with decision (decision analysis v usual care) | Decision analysis program | 201 | Satisfaction with decision as odds ratio (decision analysis v usual care) | 2 weeks post delivery (satisfaction with decision) | | | 37 weeks gestation (DCS) mean, 0.14 range,0.02 to 0.27 | | 0.063
Montgomery, 2007^8^ | Mode of delivery - elective caesarean | Usual Care | 201 | | 6 weeks post delivery | | questionnaire at 36 weeks gestation | Hospital records: type of delivery:50
Montgomery, 2007^8^ | Mode of delivery - elective caesarean | Computerized Educational Information | 201 | | 6 weeks post delivery | | questionnaire at 36 weeks gestation | Hospital records: type of delivery:49
Montgomery, 2007^8^ | Mode of delivery - elective caesarean | Decision analysis program | 198 | | 6 weeks post delivery | | questionnaire at 36 weeks gestation | Hospital records: type of delivery:41
Montgomery, 2007^8^ | Delivery - emergency caesarean | Usual Care | 238 | | 6 weeks post delivery | | questionnaire at 36 weeks gestation | Hospital records: type of delivery:20
Montgomery, 2007^8^ | Delivery - emergency caesarean | Computerized Educational Information | 240 | | 6 weeks post delivery | | questionnaire at 36 weeks gestation | Hospital records: type of delivery:22
Montgomery, 2007^8^ | Delivery - emergency caesarean | Decision analysis program | 235 | | 6 weeks post delivery | | questionnaire at 36 weeks gestation | Hospital records: type of delivery:21
Montgomery, 2007^8^ | Delivery - vaginal birth | Usual Care | 238 | | 6 weeks post delivery | | questionnaire at 36 weeks gestation | Hospital records: type of delivery:30
Montgomery, 2007^8^ | Delivery - vaginal birth | Computerized Educational Information | 240 | | 6 weeks post delivery | | questionnaire at 36 weeks gestation | Hospital records: type of delivery:29
Montgomery, 2007^8^ | Delivery - vaginal birth | Decision analysis program | 235 | | 6 weeks post delivery | | questionnaire at 36 weeks gestation | Hospital records: type of delivery:37

BL = baseline, SD = standard deviation, OR = odd ratio, RR = relative ratio, DCS = decisional conflict scale

Reference List

1 Green MJ, Peterson SK, Baker MW et al. Use of an educational computer program before genetic counseling for breast cancer susceptibility: effects on duration and content of counseling sessions. Genet Med 2005; 7(4):221–9.

2 Gustafson DH, Hawkins R, Mctavish F et al. Internet-based interactive support for cancer patients: Are integrated systems better? 2008; 58(2):238–57.

3 Gustafson DH, Hawkins R, Pingree S et al. Effect of computer support on younger women with breast cancer. J Gen Intern Med 2001; 16(7):435–45.

4 Maslin AM, Baum M, Walker JS, A'Hern R, Prouse A. Using an interactive video disk in breast cancer patient support. Nurs Times 1998; 94(44):52–5.

5 Brennan PF, Moore SM, Smyth KA. The effects of a special computer network on caregivers of persons with Alzheimer's disease. Nurs Res 1995; 44(3):166–72.

6 Flatley-Brennan P. Computer network home care demonstration: a randomized trial in persons living with AIDS. Comput Biol Med 1998; 28(5):489–508.

7 Sciamanna CN, Harrold LR, Manocchia M, Walker NJ, Mui S. The effect of web-based, personalized, osteoarthritis quality improvement feedback on patient satisfaction with osteoarthritis care. Am J Med Qual 2005; 20(3):127–37.

8 Montgomery AA, Emmett CL, Fahey T et al. Two decision aids for mode of delivery among women with previous caesarean section: randomised controlled trial. BMJ 2007; 334(7607):1305.

Evidence Table 35

Description of RCTs addressing KQ1d (impact of CHI applications on clinical outcomes)

Author, year | Consumer under study | CHI Application type | Location | Year data collected/ duration of intervention | Inclusion criteria | Exclusion criteria | Control | Intervention | Jadad score
Alzheimer’s
Tarraga, 2006^1^ | Individuals interested in their own health care | Interactive consumer website | Clinician office | NS | > 65 yr, treated with CHEI x 1 yr, > 3 yrs education, MMSE 18–24, a Global Deterioration Scale (GDS) score of 3 or 4, absence of uncontrolled disruptive behaviors, absence of major depression, absence of structural lesions in the computed tomogram, absence of history of alcohol or the substance abuse | Uncontrolled disruptive behaviors (e.g., aggression, delusions, hallucinations and agitation) that could interfere with program administration and/or neuropsychological assessments, major depression, current or partial remission, structural lesions in the computed tomogram or magnetic resonance image, history of alcohol or other substance abuse, severe auditory, visual or motor deficits that may interfere with cognitive testing | ChEI control | Integrated psycho stimulation program, Interactive Multimedia Internet-based System (IMIS) | 0
Arthritis
Lorig, 2008^2^ | Individuals interested in their own health care | Interactive consumer website | NS | 2004/NS | 18 and older, a diagnosis of OA, rheumatoid arthritis (RA), or fibromyalgia, could have other chronic conditions Internet and email access agreed to 1–2 hours per week of log-on time spread over at least 3 sessions/week for 6 weeks | Active treatment for cancer for 1 yr, participated in the small-group ASMP or the Chronic Disease Self-Management Program | Usual care | Online intervention | 1
Asthma
Jan, 2007^3^ | Individuals interested in their own health care Caregiver, childhood asthma | Personal monitoring device | Home/ residence | 2004/ January to December | 6 – 12 yr, caregivers have Internet access, persistent asthma diagnosis (GINA clinical practice guidelines) | Diagnosed with bronchopulmonary dysplasia, diagnosed with other chronic co morbid conditions that could affect quality of life | Verbal information and booklet for asthma education with written asthma diary. | Blue Angel for Asthma Kids, An internet-based diary record for peak expiratory flow rate (PEFR) symptomatic support information, and an action plan suggestion, and telecommunication technologies for uploading and retrieving the storage data | 1
Back pain
Buhrman, 2004^4^ | Individuals interested in their own health care | Interactive consumer website | Home/ residence | NS, | 18–65 yr, Internet access, Been in contact with a physician, Have back pain, Have chronic pain (>3 months), | Suffer of pain that can increase as a consequence of activity, wheelchair bound, have planned any surgical treatment, suffer from heart and vascular disease | Wait-list | Internet-based pain management program | 2
Breast cancer
Gustafson, 2001^5^ | Individuals interested in their own health care | Interactive consumer website, | Home/ residence | Duration, Between April 1995 and May 1997 | <60 years, Breast cancer patients, Within 6 months of diagnosis, not homeless, not active illegal drug users, | | Allocated standard intervention | Received CHESS intervention | 1
Gustafson, 2008^6^ | Individuals interested in their own health care | Interactive consumer website | Home/ residence | Between April 1995 and May 1997 | <60 years, Breast cancer patients, Within 6 months of diagnosis, not homeless, not active illegal drug users | | Allocated standard intervention | Received CHESS intervention | 2
Maslin, 1998^7^ | Individuals interested in their own health care | Interactive computerized video system | Clinician office | NS | Non metastatic breast cancer, | Advanced breast cancer, metastatic disease, sensory impairment, do not understand English, | Standard care | Interactive computerized video system | −1
Chronic adult aphasia
Katz, 1997^8^ | Individuals interested in their own health care | Interactive consumer website | Clinician office | NS | <85 years, aphasia subsequent to a single left hemisphere, thromboembolic infarct, completed at least 8th grade, pre-morbidly literate in English, living in non-institutionalized environment, at least one year post-onset of aphasia, performs between 15th and 90th overall percentile on the Porch Index of communicative Ability, Pre-morbidly right-handed | Visual acuity better than 20/100 corrected in the better eye, auditory acuity better than 40 dB speech reception threshold, language treatment in the three months prior to entry into the study | No treatment | Computer stimulation, Computer reading treatment | 1
COPD
Nguyen, 2008^9^ | Individuals interested in their own health care | Interactive consumer website, | Academic medical centers | 2005/ NS | Diagnosis of COPD and being clinically stable for at least 1 month, spirometry results showing at least mild obstructive disease, ADL limited by dyspnea, use of the Internet and/or checking email at least once per week with a windows operating system, oxygen saturation > 85% on room air or ¡Ü 6 L/min of nasal oxygen at the end of a 6-minute walk test, | Any active symptomatic illness, participated in a pulmonary rehabilitation program in the last 12 months, were currently participating in > 2 days of supervised maintenance exercise | Face-to-face (fDSMP) | Internet-based (eDSMP) | 2
Headache
Trautman, 2008^10^ | Individuals interested in their own health care Parents/caregivers | Interactive consumer website | Home/ residence | NS | 10–18 yr, At least two headache attacks per month | | EDU (First training session of CBT on headache information plus chat communication) | CBT (6 self-help sessions and 6 weekly chat sessions with trainer) | 3
Mental health/Depression
Christensen, 2004^11^ | Individuals interested in their own health care | Interactive consumer website | NS | NS | ≥ 18 years, internet access, 22 or higher on the Kessler psychological distress scale | ≥ 52 years, receiving clinical care from either a psychologist or psychiatrist | Control | Mood GYM Blue Pages | 2
Hasson, 2005^12^ | Individuals interested in their own health care | Personal monitoring device | NS | NS | Employment at a company insured by Alecta (occupational pension plan company) | Those who quit employment prior to completion of study, "communication related problem" | Access to web-based tool including monitoring tool for stress and health; diary connected to monitoring tool, and scientific info on stress and health | Web-based tool with control group components plus self-help with stress management exercises and chat | 2
Kerr, 2008^13^ | Individuals interested in their own health care | Interactive consumer website | Home/ residence | NS | 18 – 25 years, BMI 25–39 | | Enhanced standard care | PACEi | 1
March, 2008^14^ | Individuals interested in their own health care: childrenparents | | NS | NS | 7 – 12 yr, primary diagnosis of an anxiety disorder with severity level of 4 or more on 8 point scale ( I-e moderate severity), a minimum reading level of 8 years access to internet at home | Developmental disorders, learning disability, depressive disorder, other psychological treatment, primary behavioral disorder, failure to complete screening assessment | Wait list (WL) | | 2
Orbach, 2007^15^ | | Interactive consumer website, | Remote location: university campus | NS | Both, students in Kings College London, London University, access to a computer connected to the Internet | Receiving treatment for anxiety, | Control | CBT | 1
Proudfoot, 2003^16^ | Individuals interested in their own health care | Personal monitoring device | Clinician office | NS | 18–75 years old, depression, anxiety and depression, Anxiety, >=4 on General Health Questionnaire-12, >=12 on Clinical Interview Schedule-Revised | Psychological treatment or counseling, current Suicidal ideation, psychotic disorder organic mental disorder, alcohol and/or drug dependence, on medication for anxiety and/or depression for >=6 months immediately prior to entry, unable to read or write, unable to attend 8 session at surgery | Usual treatment | Beating the Blues intervention | 3
Spek, 2008^17^ | Individuals interested in their own health care | Interactive consumer website | Home/ residence | Duration, 12months | Age between 50 and 75 years, an Edinburgh Depression Scale (EDS) score of 12 or more, no DSM-IV diagnosis of depression, access to the internet and the ability to use the internet | Suffering from any other psychiatric disorder in immediate need of treatment and suicidal ideation | Waiting list control | Group CBT, Internet-based intervention | 2
Diabetes
Homko, 2007^18^ | Individuals interested in their own health care | Interactive consumer website, | Home/ residence | Duration, Sep 2004 to May 2006 | 18–45 years, documented GDM on 3-h oral glucose tolerance test, using the criteria of Carpenter and Coustan, 33 weeks gestation or less | Prior history of glucose intolerance outside of pregnancy, multiple gestations | Usual care, paper logbooks | telemedicine (website to document glucose levels and to communicate with health-care team) | 1
Tjam, 2006^19^ | Individuals interested in their own health care | Interactive consumer website | Clinician office | 2years duration | 65 yr, Both male and female, Internet proficient have access, have access to internet | Below40 and above65 years, blindness, little or no dexterity, education level below grade 5, ESRD , gestational diabetes | Individuals with Diabetes Education Centers program n, 20 | Individuals with interactive internet program | 1
Wise, 1986 20 Diabetes | Diabetic individuals both NIDDM and IDDM | Interactive computerized machine | Home / Res | Ns | Diabetics attending Charing Cross hospitaland having DM > 2 yrs | None specified | 3 controls Used: a. No intervention (used for Glucose control assessment) No KAP b. Just the assessment of the KAP c. Take-away corrective feedback | Interactive computerized machine
Diet/exercise/physical activity NOT Obesity
Adachi, 2007^21^ | Individuals interested in their own health care | Tailored advice based on answers to a questionnaire | Home/ residence | 2002/ January to September | 20–65 yr, BMI ≥ 24, BMI r ≥ 23 with mild hypertension Hyperlipidemia, or DM | | Untailored self-help booklet with 7-month self monitoring | behavioral weight control program with 6 | 0
Hunter, 2008^22^ | Individuals interested in their own health care | Interactive consumer website, | NS | Year, 2006 | 18 – 65 yr, weight within 5 pounds or above their maximum allowable weight (MAW) for the USAF, personal computer with internet access, plans to remain in the local area for 1 year, | Lost more than 10 pounds in the previous 3 months, used prescription or over-the-counter weight-loss medications in the previous 6 months, had any physical activity restrictions, had a history of myocardial infarction, stroke, or cancer in the last 5 years, reported diabetes, angina, or thyroid difficulties; or had orthopedic or joint problems, women were excluded if they were currently pregnant or breast-feeding, or had plans to become pregnant in the next year | Usual care | behavioral Internet treatment | 2
McConnon, 2007^23^ | Individuals interested in their own health care | Interactive consumer website, | Home/ residence | 2003/ NS | 18 – 65 yr, BMI 30 or more, able to access internet at least 1 time a week, able to read and write English | | Usual care | Internet group | 1
Tate, 2006^24^ | Individuals interested in their own health care | Interactive consumer website | Clinician office | NS, | 20 to 65, body mass index of 27 to 40, willingness to use meal replacements as part of the dietary regimen, availability of a computer with internet access | Heart attack, stroke, or cancer in the past 5 years, diabetes, angina or orthopedic or joint problems that would prohibit exercise, major psychiatric disorder involving hospitalization during the past year, current, planned, or previous (within 6 months) pregnancy | No counseling | human email counseling, automated feedback | 4
Williamson, 2006^25^ | Individuals interested in their own health care | Interactive consumer website | Clinician office | NS | 11 – 15 yr, African-American, female, BMI above the 85th percentile for age and gender based on 1999 National Health and Nutrition Examination Study normative data, at least one obese biological parent, as defined by BMI > 30, one designated parent who was overweight (BMI > 27), adolescent’s family was willing to pay $300 out-of pocket expenses toward the purchase of the computer worth >$1000, the family home had electricity and at least one functional telephone line | | Control and intervention adolescents | control and intervention parents | 2
HIV AIDS
Gustafson, 1999^26^ | Individuals interested in their own health care | Interactive consumer website | Home/ residence | NS | | Dementia, Control subject with room mate in experimental group | No intervention | Received access to CHESS | 2
Pain Tolerance
Borckardt, 2007^27^ | Individuals interested in their own health care | Computer assisted imagery system | Remote; Sound proof lab at the university | NS | | | Distraction group | Computerized Pain Management | 0
Obesity
Morgan, 2009 28 besity | Overweight and obese males | Interactive website | Home / Res | Sept to Dec 2007 | Consenting Male individuals from U of Newcastle responding to adv who were obese / overwt (BMI 25—37), 18—60 y/o. | H/o major medical problem like heart disease in past 5 years, DM, orthopedics or joint problem that would be a barrier to PA, recent weight loss of 4.5 kg or consuming meds affecting body wt. | One information session + Program booklet | SHED IT internet program w/ information session and program booklet (the program facilitates self monitoring and daily diary to which the researchers respond)

NS = not specified, yr = year, CHESS = Comprehensive Health Enhancement Support System, CBT = computer based training, eDSMP = Internet based dyspnea self-management programs, fDSMP = face-to-face dyspnea self-management programs, BMI = body mass index

Reference List

1 Tarraga L, Boada M, Modinos G et al. A randomised pilot study to assess the efficacy of an interactive, multimedia tool of cognitive stimulation in Alzheimer's disease. J Neurol Neurosurg Psychiatry 2006; 77(10):1116–21.

2 Lorig KR, Ritter PL, Laurent DD, Plant K. The internet-based arthritis self-management program: a one-year randomized trial for patients with arthritis or fibromyalgia. Arthritis Rheum 2008; 59(7):1009–17.

3 Jan RL, Wang JY, Huang MC, Tseng SM, Su HJ, Liu LF. An internet-based interactive telemonitoring system for improving childhood asthma outcomes in Taiwan. Telemed J E Health 2007; 13(3):257–68.

4 Buhrman M, Faltenhag S, Strom L, Andersson G. Controlled trial of Internet-based treatment with telephone support for chronic back pain. Pain 2004; 111(3):368–77.

5 Gustafson DH, Hawkins R, Pingree S et al. Effect of computer support on younger women with breast cancer. J Gen Intern Med 2001; 16(7):435–45.

6 Gustafson DH, Hawkins R, Mctavish F et al. Internet-based interactive support for cancer patients: Are integrated systems better? 2008; 58(2):238–57.

7 Maslin AM, Baum M, Walker JS, A'Hern R, Prouse A. Using an interactive video disk in breast cancer patient support. Nurs Times 1998; 94(44):52–5.

8 Katz RC, Wertz RT. The efficacy of computer-provided reading treatment for chronic aphasic adults. J Speech Lang Hear Res 1997; 40(3):493–507.

9 Nguyen HQ, Donesky-Cuenco D, Wolpin S et al. Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res 2008; 10(2):e9.

10 Trautmann E, Kro?ner-Herwig B. Internet-based self-help training for children and adolescents with recurrent headache: A pilot study. 2008; 36(2):241–5.

11 Christensen H, Griffiths KM, Jorm AF. Delivering interventions for depression by using the internet: randomised controlled trial. BMJ 2004; 328(7434):265.

12 Hasson D, Anderberg UM, Theorell T, Arnetz BB. Psychophysiological effects of a web-based stress management system: a prospective, randomized controlled intervention study of IT and media workers. BMC Public Health 2005; 5:78.

13 Kerr J, Patrick K, Norman G et al. Randomized control trial of a behavioral intervention for overweight women: impact on depressive symptoms. Depress Anxiety 2008; 25(7):555–8.

14 March S, Spence SH, Donovan CL. The Efficacy of an Internet-Based Cognitive-Behavioral Therapy Intervention for Child Anxiety Disorders. J Pediatr Psychol 2008.

15 Orbach G, Lindsay S, Grey S. A randomised placebo-controlled trial of a self-help Internet-based intervention for test anxiety. Behav Res Ther 2007; 45(3):483–96.

16 Proudfoot J, Goldberg D, Mann A, Everitt B, Marks I, Gray JA. Computerized, interactive, multimedia cognitive-behavioural program for anxiety and depression in general practice. Psychol Med 2003; 33(2):217–27.

17 Spek V, Cuijpers P, Nyklicek I et al. One-year follow-up results of a randomized controlled clinical trial on internet-based cognitive behavioural therapy for subthreshold depression in people over 50 years. Psychol Med 2008; 38(5):635–9.

18 Homko CJ, Santamore WP, Whiteman V et al. Use of an internet-based telemedicine system to manage underserved women with gestational diabetes mellitus. Diabetes Technol Ther 2007; 9(3):297–306.

19 Tjam EY, Sherifali D, Steinacher N, Hett S. Physiological outcomes of an internet disease management program vs. in-person counselling: A randomized, controlled trial. 2006; 30(4):397–405.

20 Wise PH, Dowlatshahi DC, Farrant S. Effect of computer-based learning on diabetes knowledge and control. 1986; 9(5):504–8.

21 Adachi Y, Sato C, Yamatsu K, Ito S, Adachi K, Yamagami T. A randomized controlled trial on the long-term effects of a 1-month behavioral weight control program assisted by computer tailored advice. Behav Res Ther 2007; 45(3):459–70.

22 Hunter CM, Peterson AL, Alvarez LM et al. Weight management using the internet a randomized controlled trial. Am J Prev Med 2008; 34(2):119–26.

23 McConnon A, Kirk SF, Cockroft JE et al. The Internet for weight control in an obese sample: results of a randomised controlled trial. BMC Health Serv Res 2007; 7:206.

24 Tate DF, Jackvony EH, Wing RR. A randomized trial comparing human e-mail counseling, computer-automated tailored counseling, and no counseling in an Internet weight loss program. Arch Intern Med 2006; 166(15):1620–5.

25 Williamson DA, Walden HM, White MA et al. Two-year internet-based randomized controlled trial for weight loss in African-American girls. Obesity (Silver Spring) 2006; 14(7):1231–43.

26 Gustafson DH, Hawkins R, Boberg E et al. Impact of a patient-centered, computer-based health information/support system. Am J Prev Med 1999; 16(1):1–9.

27 Borckardt JJ, Younger J, Winkel J, Nash MR, Shaw D. The computer-assisted cognitive/imagery system for use in the management of pain. Pain Res Manag 2004; 9(3):157–62.

28 Morgan PJ, Lubans DR, Collins CE, Warren JM, Callister R. The SHED-IT Randomized Controlled Trial: Evaluation of an Internet-based Weight-loss Program for Men. Obesity (Silver Spring) 2009.

Evidence Table 36

Description of consumer characteristics in RCTs addressing KQ 1d (impact of CHI applications on clinical outcomes)

Author,year | Control Interventions | Age | Race, n(%) | Income | Education, n(%) | SES | Gender, n(%) | Marital Status, n(%) | Other
Alzheimer’s
Tarraga, 2006^1^ | ChEI control | Mean, 76.9 SD, 4.5 | NS | NS | NS | NR | F,12
Tarraga, 2006^1^ | Integrated psycho stimulation program (PPI) | Mean, 77.4 SD, 4.7 | NS | NS | NS | NR | F,14
Tarraga, 2006^1^ | Interactive multimedia internet-based system (IMIS) | Mean, 75.8 SD, 5.9 | NS | NS | NS | NR | F,13
Arthritis
Lorig, 2008^2^ | Usual care | Mean, 52.5 range 22–89 SD, 12.2 | White non-Hispanic, 425(93.7) | NS | Mean, 15.7SD, 3.11 | NR | F, 425(90.5) | Married, 425(71.1) | Health-related web site visits last 6 months: mean, 2.85SD, 11.68
Lorig, 2008^2^ | Online intervention | Mean, 52.2 SD, 10.9 | White non-Hispanic, 441(90.9) | NS | Mean, 15.6SD, 3.09 | NR | F, 441(89.8) | Married, 441(65.5) | Health-related web site visits last 6 months mean, 2.87 SD, 11.2
Asthma
Jan, 2007^3^ | Verbal information and booklet for asthma education with written asthma diary. | Mean, 9.9 SD, 3.2 | NS | NS | NS | NR | M,28(36.8) F, 48(63.2) | | History of asthma (yr): mean, 2.1 SD, 1.2 Asthma severity: mild, 33(43.4) moderate, 35(46.1) severe, 8(10.5) Education of primary caregiver: HS diploma or below, 43 (56.6) College or above, 33 (43.4)
Jan, 2007^3^ | Participant received asthma education and with interactive asthma monitoring system | Mean, 10.9 SD, 2.5 | NS | NS | NS | NR | M,35(39.7) F, 53(60.2) | | History of asthma (yr): mean, 2.4 SD, 1.9 Asthma severity: mild, 33(37.5) moderate, 43(48.9) severe, 12(13.6) Education of primary caregiver: HS diploma or below, 58(66.0) College or above, 30 (34.0)
Back pain
Buhrman, 2004^4^ | Wait-list | Mean, 45 SD, 10.7 | NS | NS | <8 yr, 7(24.1) 8-12 yr, 6(21) 12-14 yr, 2 (6.9) 14-16 yr, 14 (48.3) | NR | M,11(37.9) F, 18(62.1) | | Sick leave: Yes, 12 (41.4) No, 17 (58.6) Pain location: back, 12 (41.4) back plus other area, 17 (58.6) Previous treatment: PT,11(37.9) chiropractor, 12 (41.4) nephropathy, 3 (10.3) Psychologist, 6 (20.7) Pain Clinic, 2 (6.9)
Buhrman, 2004^4^ | Internet-based pain management program | Mean, 43.5 SD, 10.3 | NS | NS | <8 yr, 2 (9.1) 8-12 yr, 6 (27) 12-14 yr, 3 (13.6) 14-16 yr, 11 (50) | NR | M, 8 (36.4) F,14 (63.6) | | Sick leave: Yes, 5 (22.7) No, 17 (77.3) Pain location: back, 7 (31.8) back plus other area, 15 (68.2) Previous treatment: PT, 10 (45.5) chiropractor, 8 (36.4) naprapathy, 4 (18.2) Psychologist, 3 (13.6) Pain Clinic, 1 (4.5)
Breast cancer
Gustafson, 2001^5^ | Allocated standard intervention | Mean, 44.4 median, range, SD, 7.1 | White non-Hispanic, 72 | USD>40,000, 50.8% | 12-16 yr (40.2) | NR | | Living Status: Living with Partner, (72.6) | Insurance: private Insurance, (84.7)
Gustafson, 2001^5^ | Received CHESS intervention, a home based computer system | Mean, 44.3 median, range, SD, 6.6 | White non-Hispanic, 76 | USD >40,000, (58.1) | 12-16 yr (45.8) | NR | | Living Status: Living with Partner, (71.9 ) | Insurance: private Insurance, (86)
Gustafson, 2008^6^ | Usual Care with books | NS | NS | NS | NS | NR | | | NS
Gustafson, 2008^6^ | Internet | NS | NS | NS | NS | NR | | | NS
Maslin, 1998^7^ | Standard care | Mean, 52.1 | NS | NS | NS | NR | | | NS
Maslin, 1998^7^ | IVD shared decision program | NS | NS | NS | NS | NR | | | NS
Chronic adult aphasia
Katz, 1997^8^ | No treatment | Mean, 62.8 range, 53-70SD, 5.1 | NS | NS | Mean, 13.6 yr SD, 2.2 | NR | | | NS
Katz, 1997^8^ | Computer stimulation | Mean, 66.4 range, 53-76SD, 6 | NS | NS | mean, 15 SD, 2.8 | NR | | | NS
Katz, 1997^8^ | Computer reading treatment | Mean, 61.6 range, 48-83 SD, 10 | NS | NS | Mean, 14.4 SD, 3.3 | NR | | | NS
COPD
Nguyen, 2008^9^ | Face-to-face (fDSMP), | Mean, 70.9 SD, 8.6 | White non-Hispanic, 20(100) | NS | 12-16 yr, 8(40) >16 yr, 12(60) | NR | F, 9 (45) | | Not currently employed or currently disabled or retired, 15 (75) currently smoking, 1 (5)
Nguyen, 2008^9^ | eDSMP | Mean, 68 SD, 8.3 | White non-Hispanic, 18 (95) | NS | 12-16 yr, 10(50) >16 yr, 9(50) | NR | F, 8(39) | | Not currently employed or currently disabled or retired: 13 (72) currently smoking: 2 (11)
Headache
Trautman, 2008^10^ | EDU (First training session of CBT on headache information plus chat communication) | NS | NS | NS | NS | NR | NS | NS | NS
Trautman, 2008^10^ | | Mean, 13.4 range, 10-18 SD, 2.6 | NS | NS | NS | NR | NS | NS | NS
Trautman, 2008^10^ | | Mean, 13.4 range, 10-18 SD, 2.6 | NS | NS | NS | NR | NS | NS | NS
Mental health/ Depression
Christensen, 2004^11^ | Control | Mean, 36.29 SD, 9.3 | NS | NS | Mean, 14.4 SD, 2.3 | NR | F, 124 (70) M, 54 (30) | Married cohabiting: 100 (56) Divorced/separated: 24 (14) Never married: 53 (36) | Kessler Psychological Distress Scale: mean, 18 SD, 5.7
Christensen, 2004^11^ | Mood gym | Mean, 35.85 SD, 9.5 | NS | NS | Mean, 14.6 SD, 2.4 | NR | F, 136 (75) M, 46 (25) | Married/cohabiting: 98 (54) Divorced/separated: 26 (14) Never married: 57 (31) | Kessler Psychological Distress Scale: mean, 17.9 SD, 5
Christensen, 2004^11^ | Blue Pages | Mean, 37.25 SD, 9.4 | NS | NS | Mean, 15 SD, 2.4 | NR | F, 115 (69) M, 50 (31) | Married/cohabiting: 100 (61%) Divorced/separated: 24(15) Never Married: 53 (30) | Kessler Psychological Distress Scale: mean, 17.5 median, SD, 4.9
Hasson, 2005^12^ | Access to web-based tool including monitoring tool for stress and health; diary connected to monitoring tool, and scientific info on stress and health | NS | NS | US D <25,000, 39 (22) 25,000-40,000, 106 (61) >40,000, 27 (16) | 8-12 yr, 89 (51) 2-16 yr, 83 (48) | NR | M, 112 (64) F,62 (36%) | Marital status: Married, 134 (77) Single: 38 (22
Hasson, 2005^12^ | | NS | NS | USD <25,000, 24 (18) 25,000-40,000, 76 (59) >40,000, 27 (21) | 8-12 yr, 54 (42), 12-16 yr, 73 (57) | NR | M, 75 (58) F,54 (42) | Marital status: Married: 102 (79) Single: 25 (19)
Kerr, 2008^13^ | Enhanced standard care. Standard care participants received usual advice from their provider concerning overweight; to change their physical activity and eating habits. They also received a standard set of materials summarizing recommendations for diet and exercise. | Mean, 41.6(8.9) | NS | NS | 81(14.3) | NR | | Married or living with partner: yes, 128(65.3) | Full-time employed: yes, 140(71.4) Percent with CESD score 10 or greater: yes 59(30.1) Physical activity: mean baseline total minutes moderate & vigorous activity per day: mean, 23.15
Kerr, 2008^13^ | PACEi | Mean, 40.8 SD, 8.4 | NS | NS | 105(51.2) | NR | | Married or living with partner: yes, 140(68.5) | Full-time employed: 152 (74.0) percent with CESD score 10 or greater: 50(24.4) Physical activity: mean baseline total minutes moderate & vigorous activity per day: mean, 21.05
March, 2008^14^ | Wait list (WL) | Mean, 9.09 SD, 1.44 | NS | Australian dollar <40,000, 33(12.5) 41,000–60,000, 33(34.4) 61,000–80,000, 33(15.5) 81,000–100,000, 33(6.3) >100,000, 33(31.3) | NS | NR | F, 33(57.6) M, 33(42.
March, 2008^14^ | Internet-based CBT (NET) | Mean, 9.75 SD, 1.24 | NS | Australian dollar <40,000 40(21.1) 41,000–60,000 40(26.2) 61,000–80,000, 40(15.8) 81,000–100,000,40(15.8) >100,000, 40(21.1) | NS | NR | F, 40(52.5) M,40(47.5)
Orbach, 2007^15^ | Control | Mean, 22.54 range, 20.07–24.97 SD, 5.71 | NS | NS | Yr at university: mean, 3.02 median, SD, 2.81 | NR | F, 24 (86) | | Years test anxiety: mean, 6.12 SD, 6.39 Failed exams: 14(50)
Orbach, 2007^15^ | CBT | Mean, 24.72 range, 22.36–27.09 SD, 6.89 | NS | NS | NS | NR | F, 18 (60) | | Year at university: mean, 3.18 SD, 2.53 Years test anxiety: mean, 7.59 SD, 6.67 Failed exams: 15 (50)
Proudfoot, 2003^16^ | Usual treatment | Mean, 45.7 SD, 14.1 | Black Caribbean 2 (3) Indian 3 (5) Pakistani 1 (2) White 57 (88) | NS | <5 yr, 1(1) 5-10yr, 10 (14) 11-12 yr, 17(24) 13-15yr, 15 (21) >15, 28(39) | NR | F, 57 (73.1) M, 21(26.9) | Single, 20 (27) Married, 34 (45) Cohabiting, 7 (9) Separated, 2 (3) Divorced, 8 (11) Widowed, 4 (5)
Proudfoot, 2003^16^ | Beating the Blues intervention | Mean, 43.7 SD, 14.7 | Black African: 1(1) Black Caribbean 2(3) Black other 2 (3) White 68 (88) | NS | <5yr, 0 5-10yr, 8 (10) 11-12 yr, 22 (26) 13-15yr, 15 (18) >15yr, 39 (46) | NR | F, 66 (74.2) M, 23 (25.8) | Single, 25 (29) Married, 32 (37) Cohabiting, 9 (11) Separated, 2(2) Divorced. 13 (15) Widowed, 5 (6)
Spek, 2008^17^ | Waiting list control | Mean, 55 SD, 4.6 | NS | NS | NS | NR | M, 110 F, 191
Spek, 2008^17^ | | NS | NS | NS | NS | NR | | | NS
Diabetes
Homko, 2007^18^ | Usual care, paper logbooks | Mean, 29.2 SD, 6.7 | White non-Hispanic, 6(24) Black non-Hispanic, 12(48) Latino/Hispanic, 4(16) API, 3(12) | USD <15,000, 10(40) 15,000-34,999, 3(12) 35,000-54,999, 3(12) >55,000, 3(12) missing, 6(24) | < 8 yr, 2(8) 8-12 yr, 12(48) 12-16 yr, 10(40) | NR | | | BMI: mean, 32.5 SD, 7.1 Gravidity: mean, 2.9, SD, 2.3 Glucose challenge (mg/dl): mean, 179.1 SD, 45.2 GA at diagnosis (weeks): mean, 27.7 SD, 3.8
Homko, 2007^18^ | Telemedicine (website to document glucose levels and to communicate with health-care team) | Mean, 29.8 SD, 6.6 | White non-Hispanic, 8(25) Black non-Hispanic, 14(44) Latino/Hispanic, 7(22) API, 3(9) | USD <$15,000, 8(25) $15,000-$34,999, 8(25) $35,000-$54,999, 3(9) >$55,000, 6(19) missing, 7(22) | <8 yr, 4(12.5) 8-12 yr, 12(37.5) 12-16 yr, 15(47) | NR | | | BMI : mean, 33.4 SD, 8.6 Gravidity: mean, 3 SD, 1.8 Glucose challenge (mg/dl): mean, 159.5 SD, 46.3 GA at diagnosis (weeks): mean, 27.5 SD, 4.2
Tjam, 2006^19^ | Individual with Diabetes Education Centers (DEC) program n,20 | Range, 65 | NS | NS | <8 yr, 8 (40) 8-12 yr, 3 (15) 12-16 yr, 9 (45) | NR | NS | NS | NS
Tjam, 2006^19^ | Individual with interactive internet program | Range, 65 | NS | NS | <8 yr, 8 (21.6) 8-12 yr, 5 (13.5) 12-16 yr, 24 (64.9) | NR | NS | NS | NS
Wise, 1986 20 Diabetes | IDDM | 42 +/- 16 | NS | NS | NS | | Sex ratio varied from 0.42 to 0.60. The study does not specify any other detail
Wise, 1986 20 Diabetes | Control Group (AGE +/- SE)
Wise, 1986 20 Diabetes | Assessment on KAP | 44 +/- 17
Wise, 1986 20 Diabetes | KAP –Feedback – KAP | 45 +/- 16
Wise, 1986 20 Diabetes | KAP –Interactive computer –KAP | 41 +/- 18
Wise, 1986 20 Diabetes | NIDDM | 55 +/- 21 | NS | NS | NS | | Sex ratio varied from 0.42 to 0.60. The study does not specify any other detail
Wise, 1986 20 Diabetes | Control Group (AGE +/- SE)
Wise, 1986 20 Diabetes | Assessment on KAP | 57 +/- 23
Wise, 1986 20 Diabetes | KAP –Feedback – KAP | 58 +/- 17
Wise, 1986 20 Diabetes | KAP –Interactive computer –KAP | 56 +/- 16
Diet/exercise/physical activity not obesity
Adachi, 2007^21^ | Control | Mean, 46.3 SD, 8.6 | NS | NS | NS | NR | | | Height (cm): mean, 157.6 SD, (5.9) Body weight (kg): mean, 65.1 SD, 6.4 BMI (kg/m2): mean, 26.1 SD, 1.6
Adachi, 2007^21^ | Behavioral weight control program with 6-month weight and targeted | Mean, 46.6 SD, 10.1 | NS | NS | NS | NR | | | Height: mean, 157.5 SD, 6.1 Body weight (kg): mean, 65.3 SD, 6.4 BMI (kg/m2): mean, 26.2SD, 1.4
Adachi, 2007^21^ | Untailored self-help booklet with 7-month self monitoring | Mean, 46.6 SD, 9 | NS | NS | NS | NR | | | Height: mean, 155.7 SD, 5.2 Body weight (kg): mean, 63.4 SD, 5.5 BMI (kg/m2): mean, 26.1 SD, 1.5
Hunter, 2008^22^ | Usual care | Mean, 34.4 SD, 7.2 | White non-Hispanic, 222 (53.2) | NS | 12-16 yr, 222(61.7) | NR | F, 222(50.5)
Hunter, 2008^22^ | Behavioral Internet treatment | Mean, 33.5 SD, 7.4 | White non-Hispanic, 224 (58.0) | NS | 12-16 yr, 224(63.9), | NR | F, 224(50.0)
McConnon, 2007^23^ | “usual care”. Participants randomized to the usual care group were advised to continue with their usual approach to weight loss and were given a small amount of printed information at baseline, reflecting the type of information available within primary care. | Mean, 47.4 | NS | NS | NS | NR | | | Weight (kg): mean, 94.9 kg BMI: mean, 34.4 Quality of Life (Euro QoL): mean, 61.5 Physical Activity (Baecke): mean, 6.7
McConnon, 2007^23^ | Internet group | Mean, 48.1 | NS | NS | NS | NR | | | Weight (kg): mean, 97.5 kg BMI: mean, 34.35 Quality of Life (EuroQoL): mean, 70 Physical Activity (Baecke): mean, 6.8
Tate, 2006^24^ | No counseling | Mean, 49.9 SD, 8.3 | Minority, 6 (9) | NS | >16 yr, (49) | NR | F, 55 (82 ) | | Weight: mean, 88.3 (13.9) body mass index: 32.3 (3.7) internet experiences: 4.7 (2.9)
Tate, 2006^24^ | Human email counseling | Mean, 49.7 SD, 11.4 | Minority, 8(13 ) | NS | >16 yr, (56) | NR | F, (53, 87) | | Weight: mean, 89.0 (13.0) body mass index: 32.8 (3.4) Internet experiences: 4.1 (2.3)
Tate, 2006^24^ | Automated feedback | Mean, 47.9 SD, 9.8 | Minority, 6(10) | NS | >16 yr, (59) | NR | F, 54 (84) | | Weight: mean, 89.0 (13.2) body mass index 32.7 (3.5) Internet experiences: 4.4 (2.2)
Williamson, 2006^25^ | Control and intervention adolescents | Mean, 13.2 SD, 1.4 | NS | NS | NS | NR | | | Height: mean, 160.0 cm SD, 8.1 weight: mean, 93.3 kg SD, 22.5 BMI: percentile 98.3 (2.5) mean, 36.4 SD, 7.9 body fat DXA: mean, 45.9 SD, 7.5
Williamson, 2006^25^ | Control and intervention parents | Mean, 43.2SD, 6.2 | NS | NS | NS | NR | | | Height: mean, 162.3 cm SD, 6.9 weight: mean, 101.2 kg SD, 18.4 BMI: percentile not reported mean, 38.4 SD, 7.2 body fat DXA: mean, 48.4 SD, 6.3
HIV
Gustafson, 1999^26^ | Control | Mean, 34.5 | White, non-Hispanic, (86.7) | | Mean, 14.7yr | | | Living alone mean, (31.9) | Health insured, (80.5)
Gustafson, 1999^26^ | CHESS | Mean 34.8 | White, non-Hispanic, (81.2) | | Mean, 14.3 yr | | | Living alone mean, (24) | Health insured, (75.8)
Pain
Borckardt, 2007^27^ | Distraction group | Mean, 20.29 SD, 2.38 | NS | NS | NS | NR | M, 26 F, 38 | NS
Borckardt, 2007^27^ | Computerized Pain Management | Mean, 20.52 SD, 2.86 | NS | NS | NS | NR | M, 26 F, 30 | NS
Obesity
Morgan, 2009 28 Obesity | One information session + Program booklet | 34 SD 11.6 | NS | NS | Student: 14 Non Acad Staff: 13 Acad Staff: 4 | Measured by SEIFA score 1,2-0 3,4-5 5,6-9 7,8:11 9,10:3 | All M
| SHED IT internet program w/ information session and program booklet (the program facilitates self monitoring and daily diary to which the researchers respond) | 37.5 SD 10.4 | NS | NS | Student: 14 Non Acad Staff: 14 Acad Staff: 6 | 1,2-1 3,4-7 5,6-3 7,8:11 9,10:2 | All M

NR= Not Reported, NS= Not Significant, SD= Standard Deviation, SES= Socioeconomic Status, Yr = year, M = male, F = female, API = Asian/Pacific Islander, CBT = computer-based training, kg = kilogram, BMI= Body Mass Index, QOL= Quality of Life, CHESS = Comprehensive Health Enhancement Support System

Reference List

1 Tarraga L, Boada M, Modinos G et al. A randomised pilot study to assess the efficacy of an interactive, multimedia tool of cognitive stimulation in Alzheimer's disease. J Neurol Neurosurg Psychiatry 2006; 77(10):1116-21.

2 Lorig KR, Ritter PL, Laurent DD, Plant K. The internet-based arthritis self-management program: a one-year randomized trial for patients with arthritis or fibromyalgia. Arthritis Rheum 2008; 59(7):1009-17.

3 Jan RL, Wang JY, Huang MC, Tseng SM, Su HJ, Liu LF. An internet-based interactive telemonitoring system for improving childhood asthma outcomes in Taiwan. Telemed J E Health 2007; 13(3):257-68.

4 Buhrman M, Faltenhag S, Strom L, Andersson G. Controlled trial of Internet-based treatment with telephone support for chronic back pain. Pain 2004; 111(3):368-77.

5 Gustafson DH, Hawkins R, Pingree S et al. Effect of computer support on younger women with breast cancer. J Gen Intern Med 2001; 16(7):435-45.

6 Gustafson DH, Hawkins R, Mctavish F et al. Internet-based interactive support for cancer patients: Are integrated systems better? 2008; 58(2):238-57.

7 Maslin AM, Baum M, Walker JS, A'Hern R, Prouse A. Using an interactive video disk in breast cancer patient support. Nurs Times 1998; 94(44):52-5.

8 Katz RC, Wertz RT. The efficacy of computer-provided reading treatment for chronic aphasic adults. J Speech Lang Hear Res 1997; 40(3):493-507.

9 Nguyen HQ, Donesky-Cuenco D, Wolpin S et al. Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res 2008; 10(2):e9.

10 Trautmann E, Kro?ner-Herwig B. Internet-based self-help training for children and adolescents with recurrent headache: A pilot study. 2008; 36(2):241-5.

11 Christensen H, Griffiths KM, Jorm AF. Delivering interventions for depression by using the internet: randomised controlled trial. BMJ 2004; 328(7434):265.

12 Hasson D, Anderberg UM, Theorell T, Arnetz BB. Psychophysiological effects of a web-based stress management system: a prospective, randomized controlled intervention study of IT and media workers. BMC Public Health 2005; 5:78.

13 Kerr J, Patrick K, Norman G et al. Randomized control trial of a behavioral intervention for overweight women: impact on depressive symptoms. Depress Anxiety 2008; 25(7):555-8.

14 March S, Spence SH, Donovan CL. The Efficacy of an Internet-Based Cognitive-Behavioral Therapy Intervention for Child Anxiety Disorders. J Pediatr Psychol 2008.

15 Orbach G, Lindsay S, Grey S. A randomised placebo-controlled trial of a self-help Internet-based intervention for test anxiety. Behav Res Ther 2007; 45(3):483-96.

16 Proudfoot J, Goldberg D, Mann A, Everitt B, Marks I, Gray JA. Computerized, interactive, multimedia cognitive-behavioural program for anxiety and depression in general practice. Psychol Med 2003; 33(2):217-27.

17 Spek V, Cuijpers P, Nyklicek I et al. One-year follow-up results of a randomized controlled clinical trial on internet-based cognitive behavioural therapy for subthreshold depression in people over 50 years. Psychol Med 2008; 38(5):635-9.

18 Homko CJ, Santamore WP, Whiteman V et al. Use of an internet-based telemedicine system to manage underserved women with gestational diabetes mellitus. Diabetes Technol Ther 2007; 9(3):297-306.

19 Tjam EY, Sherifali D, Steinacher N, Hett S. Physiological outcomes of an internet disease management program vs. in-person counselling: A randomized, controlled trial. 2006; 30(4):397-405.

20 Wise PH, Dowlatshahi DC, Farrant S. Effect of computer-based learning on diabetes knowledge and control. 1986; 9(5):504-8.

21 Adachi Y, Sato C, Yamatsu K, Ito S, Adachi K, Yamagami T. A randomized controlled trial on the long-term effects of a 1-month behavioral weight control program assisted by computer tailored advice. Behav Res Ther 2007; 45(3):459-70.

22 Hunter CM, Peterson AL, Alvarez LM et al. Weight management using the internet a randomized controlled trial. Am J Prev Med 2008; 34(2):119-26.

23 McConnon A, Kirk SF, Cockroft JE et al. The Internet for weight control in an obese sample: results of a randomised controlled trial. BMC Health Serv Res 2007; 7:206.

24 Tate DF, Jackvony EH, Wing RR. A randomized trial comparing human e-mail counseling, computer-automated tailored counseling, and no counseling in an Internet weight loss program. Arch Intern Med 2006; 166(15):1620-5.

25 Williamson DA, Walden HM, White MA et al. Two-year internet-based randomized controlled trial for weight loss in African-American girls. Obesity (Silver Spring) 2006; 14(7):1231-43.

26 Gustafson DH, Hawkins R, Boberg E et al. Impact of a patient-centered, computer-based health information/support system. Am J Prev Med 1999; 16(1):1-9.

27 Borckardt JJ, Younger J, Winkel J, Nash MR, Shaw D. The computer-assisted cognitive/imagery system for use in the management of pain. Pain Res Manag 2004; 9(3):157-62.

28 Morgan PJ, Lubans DR, Collins CE, Warren JM, Callister R. The SHED-IT Randomized Controlled Trial: Evaluation of an Internet-based Weight-loss Program for Men. Obesity (Silver Spring) 2009.

Evidence Table 37

All outcomes KQ 1d, impact of CHI applications on clinical outcomes

Author, year | Outcome | Control Intervention | n | Measure at BL | Measure at time point 2 | Measure at time point 3 | Measure at time point 4 | Measure at final time point | Ratios at time points | Significance
Alzheimer’s
Tarraga, 2006^1^ | Alzheimer’s Disease Assessment Scale-Cognitive | Control | 12 | Mean, 20 SD, 4.35 | | | | 24wks: mean, 21.83 SD, 4.48
Tarraga, 2006^1^ | Alzheimer’s Disease Assessment Scale-Cognitive | IMIS, IPP, ChEIs | 15 | Mean, 22.4 SD, 5.7 | | | | 24wks: mean, 21.33 SD, 5.74
Tarraga, 2006^1^ | Alzheimer’s Disease Assessment Scale-Cognitive | IPP, ChEIs | 16 | Mean, 21.19 SD, 5.73 | | | | 24wks: mean, 22.31 SD, 6.81
Arthritis
Lorig, 2008^2^ | Health distress | Control | 344 | Mean, 2.37 SD, 1.19 | 6mos | | | 1yr: mean, 2.25 SD, 1.19 | | p<0.001
Lorig, 2008^2^ | Health distress | Online intervention | 307 | Mean, 2.41 SD, 1.2 | 6mos | | | 1yr: mean, 2 SD, 1.18
Lorig, 2008^2^ | Activity limitation | Control | 344 | Mean, 3.22 SD, 0.903 | 6mos | | | 1yr mean, 3.29 SD, 0.885 | | p<0.001
Lorig, 2008^2^ | Activity limitation | Online intervention | 307 | Mean, 3.17 SD, 0.973 | 6mos | | | 1yr mean, 3.09 SD, 0.962
Lorig, 2008^2^ | Self reported global health | Control | 344 | Mean, 0.569 SD, 0.446 | 6mos | | | 1yr mean, 0.573 SD, 0.457 | | P< 0.004
Lorig, 2008^2^ | Self reported global health | Online intervention | 307 | Mean, 0.547 SD, 0.401 | 6mos | | | 1yr mean, 0.514 SD, 0.445
Lorig, 2008^2^ | Pain | Control | 344 | Mean, 6.37 SD, 2.22 | 6mos | | | 1yr mean, 6.1 SD, 2.35 | | p<0.001
Lorig, 2008^2^ | Pain | Online intervention | 307 | | 6mos | | | 1yr mean, 5.77 SD, 2.53
Lorig, 2008^2^ | Self efficacy | Control | 344 | Mean, 4.96 SD, 1.98 | 6mos | | | 1yr: mean, 5.34 SD, 2.06
Lorig, 2008^2^ | Self efficacy | Online intervention | 307 | Mean, 5.08 SD, 2.13 | 6mos | | | 1yr: mean, 5.89 SD, 2.09
Asthma
Jan, 2007^3^ | Symptom score at nighttime | Control | 71 | Mean, 0.05 median, 0 SD, 0.13 | | | | Week 12: mean, 0.05; median, 0; SD, 0.19
Jan, 2007^3^ | Symptom score at nighttime | Participants received asthma education and with interactive asthma monitoring system | 82 | Mean, 0.11 median, 0 range, 0.00–0.58 SD, 0.28 | | | | Week 12 mean, 0.04 median, 0 range, 0.00–1027 SD, 0.17
Jan, 2007^3^ | Symptom score at daytime | Control | 71 | Mean, 0.03 median, 0 range, 0.00–0.58 SD, 0.11 | | | | Week 12 mean, 0.05 median, 0 range, 0.00–0.91 SD, 0.07
Jan, 2007^3^ | Symptom score at daytime | Participants received asthma education and with interactive asthma monitoring system | 82 | Mean, 0.14 median, 0 range, 0.00–1.17 SD, 0.32 | | | | Week 12
Jan, 2007^3^ | Morning PEF | Control | 71 | Mean, 219.2 median, 212.7 range, 125.0–361.9 SD, 58.0 | | | | Week12: mean, 230.0 median, 229.6 range, 147.5–374.2 SD, 57.9 | | p<0.072
Jan, 2007^3^ | Morning PEF | Participants received asthma education and with interactive asthma monitoring system | 82 | Mean, 223.1 median, 214.6 range, 128.2–385.0 SD, 55.5 | | | | Week, 12 mean, 241.9 median 220.0 range, 126.7–594.3 SD, 81.4 | | p <0.017
Jan, 2007^3^ | Night PEF | Control | 71 | Mean, 224.7 median, 213.8 range, 107.5–356.6 SD, 57.6 | | | | Week, 12 mean, 235.9 median, 232.1 range, 142.5–428.4 SD, 61.6 | | p<0.070
Jan, 2007^3^ | Night PEF | Participants received asthma education and with interactive asthma monitoring system | 82 | Mean, 232.5 median 223.3 range, 141.4–389.4 SD, 55.3 | | | | Week, 12 mean, 255.6 median, 244.1 range, 123.3–655.5 SD, 86.7 | | p<0.010
Back pain
Buhrman, 2004^4^ | CSQ-Catastrophizing | Control | 29 | Mean, 13.7 SD, 6.9 | | | | 2 mos mean, 12.3 SD, 7.2 | | p<0.01
Buhrman, 2004^4^ | CSQ-Catastrophizing | Cognitive Behavior Intervention | 22 | Mean, 13.6 SD, 7.7 | | | | 2 mos mean, 8.6 SD, 5.2
Buhrman, 2004^4^ | CSQ-Ability to decrease pain | Control | 29 | Mean, 2.6 SD, 1.0 | | | | 2 mos mean, 2.9 SD, .1.0 | | p<0.05
Buhrman, 2004^4^ | CSQ-Ability to decrease pain | Cognitive Behavior Intervention | 22 | Mean, 3.0 SD, 0.8 | | | | 2 mos mean, 3.9 SD, 0.9
Buhrman, 2004^4^ | CSQ-Control over pain | Control | 29 | Mean, 2.9 SD, 1.1 | | | | 2 mos: mean, 2.9 SD, 1 | | p<0.05
Buhrman, 2004^4^ | CSQ-Control over pain | Cognitive Behavior Intervention | 22 | Mean, 2.8 SD, 1 | | | | 2 mos: mean, 3.9 SD, 0.7
Breast cancer
Gustafson, 2001^5^ | Social/family well being (quality of life) | Control | 125 | | 2 mos mean, 78.2 | | | 5 mos: mean, 74.7
Gustafson, 2001^5^ | Social/family well being (quality of life) | Chess | 121 | | 2 mos mean, 79.3 | | | 5 mos: mean, 75.8
Gustafson, 2001^5^ | Emotional well-being (quality of life) | Control | 125 | | 2 mos mean, 72.8 SD, | | | 5 mos mean, 75.3
Gustafson, 2001^5^ | Emotional well-being (quality of life) | CHESS | 121 | | 2 mos mean, 73.9 | | | 5 mos mean, 76.3
Gustafson, 2001^5^ | Functional well-being (quality of life) | Control | 125 | | 2 mos mean, 63.0 | | | 5 mos mean, 69.9
Gustafson, 2001^5^ | Functional well-being (quality of life) | CHESS | 121 | | 2 mos mean, 62.2 | | | 5 mos mean, 70.4
Gustafson, 2001^5^ | Breast cancer concerns (quality of life) | Control | 125 | | 2 mos mean, 63.3 | | | 5 mos mean, 64.7
Gustafson, 2001^5^ | Breast cancer concerns (quality of life) | CHESS | 121 | | 2 mos mean, 65.1 | | | 5 mos mean, 67.6
Gustafson, 2008^6^ | Quality of life | Control | 80 | Mean, 0.18 SD, 0.53 | | | | 9 mos: mean, 0.11 SD, 0.45 | | BL, .058 .039 .126 Time point 2, .24 .004 .32 Final time point, .018 .021 .028
Gustafson, 2008^6^ | Quality of life | Internet | 75 | Mean, −0.02 SD, 0.56 | | | | 9 mos: mean, 0.07 SD, 0.45 | | BL, .84 .39 .69 Time point 2, 44 .77 .53 Final time point, .33 .57 .48
Gustafson, 2008^6^ | Quality of life | CHESS | 80 | Mean, 0.02 SD, 0.54 | | | | 9 mos: mean, 0.18 SD, 0.54 | | BL, .029 .003 .007 Time point 2, 0.47 .027 .15 Final time point, .14 .14 .16
Maslin, 1998^7^ | Anxiety and depression | Control | 48 | Score on HAD | | | | 9 mos later | | p<0.001
Maslin, 1998^7^ | Anxiety and depression | IVD shared decision program | 51 | | | | | 9 mos later
Chronic adult aphasia
Katz, 1997^8^ | Porch Index of Communicative Ability (percentiles) Overall | Control | 15 | Mean, 59.5 SD, 16.2 | | | | Week, 26 mean, 61.3 SD, 17.4
Katz, 1997^8^ | Porch Index of Communicative Ability (percentiles) Overall | Computer reading treatment | 21 | Mean, 57.3 SD, 17.9 | | | | Mean, 66.4 SD, 19.4 | | p<.01
Katz, 1997^8^ | Porch Index of Communicative Ability (percentiles) Overall | Computer stimulation | 19 | Mean, 51.9 SD, 20.3 | | | | Mean, 56.3 SD, 20.9 | | p<.01
Katz, 1997^8^ | Porch Index of Communicative Ability (percentiles) Verbal | Control | 15 | Mean, 55.6 SD, 16.0 | | | | Week, 26 mean, 58.1 SD, 19.1
Katz, 1997^8^ | Porch Index of Communicative Ability (percentiles) Verbal | Computer reading treatment | 21 | Mean, 54.4 SD, 17.8 | | | | Mean, 62.3 SD, 22.3 | | p<.01
Katz, 1997^8^ | Porch Index of Communicative Ability (percentiles) Verbal | Computer stimulation | 19 | Mean, 49.3 SD, 24.6 | | | | Mean, 50.6 SD, 24.5
Katz, 1997^8^ | Western Aphasia Battery Aphasia “Quotient” | Control | 15 | Mean, 72.2 SD, 24.8 | | | | Week, 26 mean, 72.2 SD, 23.7
Katz, 1997^8^ | Western Aphasia Battery Aphasia “Quotient” | Computer reading treatment | 21 | Mean, 68.9 SD, 24.3 | | | | Mean, 73.6 SD, 22.6 | | p<.01
Katz, 1997^8^ | Western Aphasia Battery Aphasia “Quotient” | Computer stimulation | 19 | Mean, 61.9 SD, 29.5 | | | | Mean, 63.4 SD, 28.5
Katz, 1997^8^ | Western Aphasia Battery Aphasia “Repetition” | Control | 15 | Mean, 7.0 SD, 3.2 | | | | Week, 26 mean, 6.7 SD, 3.4
Katz, 1997^8^ | Western Aphasia Battery Aphasia “Repetition” | Computer reading treatment | 21 | Mean, 6.7 SD, 3.0 | | | | Mean, 7.3 SD, 2.9 | | p<.01
Katz, 1997^8^ | Western Aphasia Battery Aphasia “Repetition” | Computer stimulation | 19 | Mean, 6.0 SD, 3.5 | | | | Mean, 6.1 SD, 3.4
COPD
Nguyen, 2008^9^ | Score on CRQ subscale for dyspnea with ADLs | Control | 20 | Score o n CRQ dyspnea subscale (score range from 5–35) rating 5 activities ion a Likert scale of 1–7 points. mean, 15.9 SD, 5.4 | 3 mos mean, 19.2 SD, 5.8 | | | 6 mos: mean, 19.9 SD, 6.2 | | BL, time point 2, improvement over time is statistically significant p<0.001 final time point, improvement over time is statistically significant p<0.001
Nguyen, 2008^9^ | Score on CRQ subscale for dyspnea with ADLs | Electronic dyspnea self management program | 19 | Mean, 18.8 SD, 6.2 | 3 mos mean, 22.3 SD, 4.6 | | | 6 mos: mean, 21.3 SD, 6 | | BL, time point 2, significant change from baseline. No significant difference between intervention & control groups. final time point, significant change from baseline. NO difference between control & intervention groups. p, 0.14
Headache
Trautman, 2008^10^ | Frequency | Control | 8 | Number of headaches mean, 13.8 SD, 10.1 | Post-treatment mean, 12.3 SD, 8.6 | | | 6 mos follow-up
Trautman, 2008^10^ | Frequency | CBT | 8 | Number of headaches mean, 15.2 SD, 10.9 | Post-treatment mean, 8.1 SD, 8 | | | 6 mos follow-up: mean, 8 SD, 7.8 | | <0.05
Trautman, 2008^10^ | Duration | Control | 8 | Duration of headaches: mean, 6 SD, 5–24 | post-treatment mean, 5.1 SD, 2–23 | | | 6 mos follow-up
Trautman, 2008^10^ | Duration | CBT | 8 | Duration of headaches: mean, 3.8 SD, 2–24 | Post-treatment mean, 3.5 SD, 2.24 | | | 6 mos follow-up mean, 3.3 SD, 1.23 | | >0.05
Trautman, 2008^10^ | Intensity | | 8 | Intensity of Headaches mean, 5.8 SD, 1.5 | Post-treatment mean, 5 SD, 1.3 | | | 6 mos follow-up
Trautman, 2008^10^ | Intensity | CBT | 8 | Intensity of Headaches mean, 4.7 SD, 0.8 | Post-treatment mean, 4.7 SD, 1.3 | | | 6 mos follow-up mean, 4.2 SD, 1.9 | | >0.05
Trautman, 2008^10^ | Pain catastrophizing | | 8 | PCS-C mean, 36.4 SD, 9.7 | Post-treatment mean, 37.3 SD, 7.9 | | | 6 mos follow-up
Trautman, 2008^10^ | Pain catastrophizing | CBT | 8 | Mean, 30 SD, 5.9 | Post-treatment | | | 6 mos follow-up mean, 28.3 SD, 5.8 | | <0.05
Mental Health (Depression/Anxiety)
Christensen, 2004^11^ | Center for Epidemiologic depression scale | | 159 | Mean score point improvement over baseline mean, 21.6 SD, 11.1 | | | | 6 wks: mean, 1.1 SD, 8.4
Christensen, 2004^11^ | Center for Epidemiologic depression scale | Blue Pages: Computer based psycho education website offering information about depression | 136 | Mean score point improvement over baseline mean, 21.1 SD, 10.4 | | | | 6 wks mean, 3.9 SD, 9.1
Christensen, 2004^11^ | Center for Epidemiologic depression scale | Mood GYM: Computer based Cognitive Behavior therapy | 136 | Mean score point improvement over baseline mean, 21.8 SD, 10.5 | | | | 6 wks mean, 4.2 SD, 9.1
Hasson, 2005^12^ | Biological marker: dehydroeoiandosterone sulphate | Control | 156 | Changes in self rated measures and biological markers covariated for baseline scores | | | | 6 mos follow up | | Time*group effect, .04
Hasson, 2005^12^ | Biological marker: dehydroeoiandosterone sulphate | Web-based stress Management system | 121 | Changes in self rated measures and biological markers covariated for baseline scores | | | | 6 mos follow-up | | Time*group effect, .04
Hasson, 2005^12^ | Nero peptide | Control | 156 | Changes in self rated measures and biological markers covariated for baseline scores | | | | 6 mos Follow- up | | Time*group effect, .002
Hasson, 2005^12^ | Nero peptide | Web-based stress management system | 121 | Changes in self rated measures and biological markers covariated for baseline scores | | | | 6 mos follow up | | Time*group effect, .002
Hasson, 2005^12^ | Chromogranin | Control | 156 | Changes in self rated measures and biological markers covariated for baseline scores | | | | 6 mos follow up | | Time*group effect, .001
Hasson, 2005^12^ | Chromogranin | Web-based stress management system | 121 | Changes in self rated measures and biological markers covariated for baseline scores | | | | 6 mos follow up | | Time*group effect, .001
Kerr, 2008^13^ | CES-D score | Control | 146 | CES-D score (10 or greater probable depression)mean, 7.5 SD, 4.43 | 6 mos | | | 12 mos
Kerr, 2008^13^ | CES-D score | PACEi | 146 | CESD score (10 or greater probable depression)mean, 7.38 SD, 4.96 | 6 mos | | | 12 mos | | BL, time point 2, non significant final time point, non significant
March, 2008^14^ | Clinical severity rating | Control | | Mean, 5.83 SD, 0.6 | Post treatment at 10 wks mean, 5.14 SD, 1.43 | at 6 mos
March, 2008^14^ | Clinical severity rating | Web based intervention | | Mean, 6.07 SD, 0.58 | Post treatment at 10 wks mean, 4.3 SD, 1.58 | at 6 mos mean, 2.32 SD, 1.78 | | | | BL, time point 2, significant difference of intervention vs. control time point 3, significant diff of post treatment (point 2) vs. Follow up (point 3)
March, 2008^14^ | Children global assessment score | Control | | Mean, 51.72 SD, 5.24 | Post treatment at 10 wks mean, 54.93 SD, 8.91 | at 6 mos
March, 2008^14^ | Children global assessment score | Web based intervention | | Mean, 50.87 SD, 3.95 | Post treatment at 10 wks mean, 61.73 SD, 8.71 | at 6 mos mean, 73.67 SD, 9.14 | | | | BL, time point 2, significant intervention vs. control time point 3, sig. post treatment vs. follow up)
March, 2008^14^ | Does not meet criteria for any anxiety disorder | Control | 1 | | 10 wks: 3.4 | 6 mos | | | | Time point 2, 0.09 (intervention vs. control)
March, 2008^14^ | Does not meet criteria for any anxiety disorder | Web based intervention | 17 | | 10 wks: 16.7 | 6 mos: 60.7
Orbach, 2007^15^ | Test Anxiety Inventory | Control | 28 | Mean, 59.18 SD, 12.20 | | | | Post treatment: mean, 54.25 SD, 11.31
Orbach, 2007^15^ | Test Anxiety Inventory | Cognitive Behavior Therapy group (CBT) | 30 | Mean, 58.14 SD, 8.43 | | | | Post treatment: mean, 47.31 SD, 9.49
Orbach, 2007^15^ | Anxiety Hierarchy Questionnaire | Control | 28 | Mean, 12.73 SD, 1.66 | | | | Post treatment mean, 12.62 SD, 2.04
Orbach, 2007^15^ | Anxiety Hierarchy Questionnaire | Cognitive Behavior Therapy group (CBT) | 30 | Mean, 12.64 SD, 1.67 | | | | Post treatment mean, 10.38 SD, 3.45
Orbach, 2007^15^ | AH tests (perceptual and numerical) | Control | 28 | AH test mean, 48.74 SD, 8.18 | | | | Post treatment mean, 51.58 SD, 9.82
Orbach, 2007^15^ | AH tests (perceptual and numerical) | Cognitive Behavior Therapy group (CBT) | 30 | Mean, 44.55 SD, 13.32 | | | | Post treatment mean, 46.6 SD, 13.3
Orbach, 2007^15^ | General Self-Efficacy Scale | Control | 28 | Mean, 53.46 SD, 13.09 | | | | Post treatment: mean, 44.69 SD, 7.67
Orbach, 2007^15^ | General Self-Efficacy Scale | Cognitive Behavior Therapy group (CBT) | 30 | Mean, 57.97 SD, 7.84 | | | | Post treatment: mean, 60.24 SD, 7.67
Proudfoot, 2003^16^ | BDI(beck depression inventory) | Control | 42 | Mean, 24.08 SD, 9.78 | | | | 6mos mean, 16.07 SD, 13.06
Proudfoot, 2003^16^ | BDI(beck depression inventory) | beating the blues | 44 | Mean, 25.38 SD, 11.05 | | | | 6mos mean, 9.61 SD, 10.06
Proudfoot, 2003^16^ | BAI (beck anxiety inventory) | Control | 38 | Mean, 19.39 SD, 9.72 | | | | 6mos mean, 11.32 SD, 9.61
Proudfoot, 2003^16^ | BAI (beck anxiety inventory) | beating the blues | 40 | Mean, 18.33 SD, 9.61 | | | | 6mos mean, 8.73 SD, 7.66
Proudfoot, 2003^16^ | WSA (work and social adjustment scale) | Control | 42 | Mean, 18.46 SD, 8.25 | | | | 6mos mean, 12.1 SD, 10.11
Proudfoot, 2003^16^ | WSA (work and social adjustment scale) | Beating the blues | 45 | Mean, 19.89 SD, 9.29 | | | | 6mos mean, 9.11 SD, 8.97
Spek, 2008^17^ | Treatment response after 1 yr treatment | Control | 58 | Mean, 18.31 SD, 7.88 | | | | 12mos: mean, 12.88 SD, 10.1
Spek, 2008^17^ | Treatment response after 1 yr treatment | Group CBT | 66 | Mean, 17.99 SD, 9.39 | | | | 12mos: mean, 12.14 SD, 8.76
Spek, 2008^17^ | Treatment response after 1 yr treatment | Internet based intervention | 58 | Mean, 19.07 SD, 7.04 | | | | 12mos: mean, 10.45 SD, 8.05
Diabetes
Homko, 2007^18^ | Insulin therapy | Control | 25 | | | | 4(n,1)
Homko, 2007^18^ | Insulin therapy | Telemedicine | 28 | | | | 31 (n,10)
Homko, 2007^18^ | FBS | Control | 25 | FBS mg/dl | | | | 37 wks gestation mean, 88.6 SD, 9.5
Homko, 2007^18^ | FBS | Telemedicine | 32 | | | | | 37 wks gestation mean, 90.8 SD, 11.8 | | Non significant
Homko, 2007^18^ | A1c at time of delivery | Control | 25 | A1c at delivery (%) | | | | 37 wks gestation mean, 6.2 SD, 2.2
Homko, 2007^18^ | A1c at time of delivery | Telemedicine | 32 | | | | | 37 wks gestation mean, 6.1 SD, 0.8 | | Non significant
Tjam, 2006^19^ | A1C (%) | Control | 19 | Mean, 6.8 SD, 1.0 | 3 mos mean, 6.8 SD, 1 | | | 12 mos: mean, SD,
Tjam, 2006^19^ | A1C (%) | Individuals with interactive internet program | 34 | Mean, 6.7 SD, 1 | 3 mos mean, 6.5 SD, 1 | | | 12 mos: mean, SD,
Tjam, 2006^19^ | FBG (MMOL/L) | Control | 8 | Mean, 7.98 SD, 2.07 | 3 mos | 6 mos | | 12 mos mean, 7.71 SD, 2.14
Tjam, 2006^19^ | FBG (MMOL/L) | Individuals with interactive internet program | 17 | Mean, 8.51 SD, 2.46 | 3 mos | 6 mos | | 12 mos mean, 8.02 SD, 2.17
Tjam, 2006^19^ | TC (MMOL/L | Control | 9 | mean, 5.38 SD, 1.13 | 3 mos | 6 mos | | 12 mos mean, 4.6 SD, 0.9
Tjam, 2006^19^ | TC (MMOL/L | Individuals with interactive internet program | 16 | Mean, 4.98 SD, 1.11 | 3 mos | 6 mos | | 12 mos mean, 5.15 SD, 1.42
Tjam, 2006^19^ | TG (MMOL/L) | Control | 14 | Mean, −0.09 SD, 0.12 | 3 mos | 6 mos mean, 2.1 SD, 0.76 | | 12 mos
Tjam, 2006^19^ | TG (MMOL/L) | Individuals with interactive internet program | 24 | | 3 mos mean, 1.9 SD, 1.1 | 6 mos | | 12 mos
Wise, 1986 20 Diabetes | IDDM Patients
Wise, 1986 20 Diabetes | Knowledge Index (KAP Questionnaire) 4—6mo | Assessment of KAP only | 24 | Knowledge Score: 79 SE 2 | | | | 82 SE 2 | | Ns
Wise, 1986 20 Diabetes | Knowledge Index (KAP Questionnaire) 4—6mo | Assessment + Feedback | 22 | 78 SE 2 | | | | 83 SE 3 | | significant
Wise, 1986 20 Diabetes | Knowledge Index (KAP Questionnaire) 4—6mo | Assessment + Interactive computer | 20 | 77 SE 2 | | | | 83 SE 2 | | Significant
Wise, 1986 20 Diabetes | NIDDM Patients | | | | | | | | | NIDDM Patients
Wise, 1986 20 Diabetes | Knowledge Index (KAP Questionnaire) 4—6mo | Assessment of KAP only | 22 | Knowledge UNS | | | | UNS | | Ns
Wise, 1986 20 Diabetes | Knowledge Index (KAP Questionnaire) 4—6mo | Assessment + Feedback | 24 | 64 SE 2 | | | | 73 SE 2 | | significant
Wise, 1986 20 Diabetes | Knowledge Index (KAP Questionnaire) 4—6mo | Assessment + Interactive computer | 21 | 60 SE 3 | | | | 70 SE 2 | | Significant
Wise, 1986 20 Diabetes | IDDM Patients | | | | | | | | | IDDM Patients
Wise, 1986 20 Diabetes | Knowledge Index (KAP Questionnaire) 4—6mo | Control | 20 | HBA1c: 8.9% | | | | 8.8% | | NS
Wise, 1986 20 Diabetes | Knowledge Index (KAP Questionnaire) 4—6mo | Assessment of KAP only | 24 | 9.1 SE 0.2 | | | | 8.4 SE 0.1 | | Significant
Wise, 1986 20 Diabetes | Knowledge Index (KAP Questionnaire) 4—6mo | Assessment + Feedback | 22 | 9.3 SE 0.5 | | | | 8.1 SE 0.4 | | significant
Wise, 1986 20 Diabetes | Knowledge Index (KAP Questionnaire) 4—6mo | Assessment + Interactive computer | 20 | 9.3 SE 0.2 | | | | 8.6 SE 0.3 | | Significant
Wise, 1986 20 Diabetes | NIDDM Patients | | | | | | | | | NIDDM Patients
Wise, 1986 20 Diabetes | Knowledge Index (KAP Questionnaire) 4—6mo | Control | 21 | HBA1c: 8.7% | | | | 8.5% | | NS
Wise, 1986 20 Diabetes | Knowledge Index (KAP Questionnaire) 4—6mo | Assessment of KAP only | 22 | 9.6 SE 0.4 | | | | 8.8 SE 0.3 | | Significant
Wise, 1986 20 Diabetes | Knowledge Index (KAP Questionnaire) 4—6mo | Assessment + Feedback | 24 | 9.2 SE 0.4 | | | | 7.9 SE 0.4 | | significant
Wise, 1986 20 Diabetes | Knowledge Index (KAP Questionnaire) 4—6mo | Assessment + Interactive computer | 21 | 8.7 SE 0.7 | | | | 7.9 SE 0.6 | | Significant
Diet/exercise/physical activity not obesity
Adachi, 2007^21^ | % weight loss | Control (Group B) | 50 | | 1 mos mean, −0.05 SD, 1.4 | 3 mos mean, −1.6 SD, 2.3 | | 7 mos mean, −2.2 SD, 3.5 | | BL, time point 2, 0.01 time point 3, 0.01 final time point, 0.05
Adachi, 2007^21^ | % weight loss | Computer tailored program with 6-mos weight and targeted behavior's self-monitoring, (Group KM) | 36 | | 1 mos mean, −1.8 SD, 1.9 | 3 mos mean, −3.6 SD, 3.3 | | 7 mos mean, 4.7 SD, 4.5 | | BL, time point 2, 0.01 time point 3, 0.01 final time point, 0.05
Adachi, 2007^21^ | | Computer tailored program only, (Group K) | 44 | | 1 mos mean, −1.5 SD, 1.6 | 3 mos mean, −2.6 SD, 2.8 | | 7 mos mean, −3.3 SD, 4.3 | | BL, time point 2, 0.01 time point 3, 0.01 final time point, 0.01
Adachi, 2007^21^ | | untailored self-help booklet with 7-mos self-monitoring of weight and walking, (Group BM) | 53 | | 1 mos mean, −0.08 SD, 1.3 | 3 mos mean, −2 SD, 2.5 | | 7 mos mean, −2.6 SD, 3.4 | | BL, time point 2, 0.01 time point 3, 0.01 time point 4, final time point, 0.05
Hunter, 2008^22^ | Body weight (kg) | Control | 222 | Mean, 86.6 SD, 14.7 | | | | 6mos: mean, 87.4 SD, 14.7
Hunter, 2008^22^ | Body weight (kg) | BIT | 224 | Mean, 87.4 SD, 15.6 | | | | 6mos: mean, 85.5 SD, 15.8
McConnon, 2007^23^ | Loss of 5% or more body weight (12 mos) | Control | 77 | | | 6 mos | | 12 mos: 18
McConnon, 2007^23^ | Loss of 5% or more body weight (12 mos) | internet group | 54 | | | 6 mos | | 12 mos: 22
Tate, 2006^24^ | Weight loss | Control | 59 | | 3mos mean, −2.8 SD, 3.5 | | | 6 mos mean, −2.6 SD, 5.7
Tate, 2006^24^ | Weight loss | Tailored Computer-Automated Feedback | 44 | | 3mos mean, −5.3 SD, 4.2 | | | 6mos mean, −4.9 SD, 5.9
Tate, 2006^24^ | Weight loss | Human Email Counseling (HC) | 52 | | 3mos mean, −6.1 SD, 3.9 | | | 6mos mean, −7.3 SD, 6.2
Williamson, 2006^25^ | Body weight (kg) | Control | 50 | | | | | 24 mos: mean A,6.3 P, −0.06 SD, A,1.6 P,0.89
Williamson, 2006^25^ | Body weight (kg) | Interactive Nutrition education program and internet counseling behavioral therapy for the intervention group | 47 | | | | | 24 mos: mean A: 4.4 P: −1.1 SD A: 1.7 P: 0.91
Williamson, 2006^25^ | BMI | Control | 50 | | 6 mos | 12 mos | 18 mos | 24 mos mean A:1.2, P:0.04 SD A:.65, P;.34
Williamson, 2006^25^ | BMI | Interactive Nutrition education program and internet counseling behavioral therapy for the intervention group | 47 | Mean, A:36.4, P;38.4 SD A:7.9, P:7.2 | 6 mos | 12 mos | 18 mos | 24 mos mean A:0.73, P: −0.55 SD A:.66, P:0.34
Williamson, 2006^25^ | Weight loss behavior (body fat %) | Control | 50 | | 6 mos | 12 mos | 18 mos | 24 mos mean A:0.84, P:0.51 SD, A:0.72, P:0.46
Williamson, 2006^25^ | Weight loss behavior (body fat %) | Interactive Nutrition education program and internet counseling behavioral therapy for the intervention group | 47 | Mean A:45.9, P:48.4 SD A:7.5 P:6.3 | 6 mos | 12 mos | 18 mos | 24 mos mean, A: −.08, P:0.36 SD A:0.71, P:0.46
Williamson, 2006^25^ | BMI (percentile) | Control | 50 | BMI | 6 mos | 12 mos | 18 mos | 24 mos mean, A: −0.001 SD, A:0.003
Williamson, 2006^25^ | BMI (percentile) | Interactive Nutrition education program and internet counseling behavioral therapy for the intervention group | 47 | | 6 mos | 12 mos | 18 mos mean A: −0.004 SD A:0.003 | 24 mos
HIV
Gustafson, 1999^26^ | Active life | Control | 97 | | | | | 1.37(22) | | p<0.034
Gustafson, 1999^26^ | Active life | CHESS | 107 | | | | | 1.66(27)
Gustafson, 1999^26^ | Social support | Control | 97 | | | | | 4.24(24) | | p<0.017
Gustafson, 1999^26^ | Social support | CHESS | 107 | | | | | 4.47(27)
Gustafson, 1999^26^ | Participation in health care | Control | 97 | | | | | 3.64(23) | | p<0.020
Gustafson, 1999^26^ | Participation in health care | CHESS | 107 | | | | | 4.15(24)
Pain
Borckardt, 2007^27^ | Cold Pressor Tolerance | Control | 64 | Seconds | | | | Immediate post: mean, 73.25
Borckardt, 2007^27^ | | CACIS | 56 | Seconds | | | | Immediate post: mean, 86.25
Obesity
Morgan, 2009^28^ Obesity | Change in body wt. 3m | Prog info + Booklet gp | 31 | Loss of Weight: −3.0 (−4.5, −1.4) KG | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | | SHED IT group | 34 | Loss of Weight: −4.8 (−6.4, −3.3) KG | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | Change in body wt. 6m | Prog info + Booklet gp | 31 | Loss of Weight: −3.5 (−5.5, −1.4) | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | | SHED IT group | 34 | Loss of Weight: −5.3 (−7.3, −3.3) | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | Waist circumference (cm) 3m | Prog info + Booklet gp | 31 | LOSS: −4.4 (−6.3, −2.5) CM | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | | SHED IT group | 34 | LOSS: −5.2 (−7.1, −3.4) CM | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | Waist circumference (cm) 6m | Prog info + Booklet gp | 31 | −5.6 (−7.7, −3.5) CM | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | | SHED IT group | 34 | −7.0 (−9.1, −4.9) CM | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | BMI (kg/m2) 3m | Prog info + Booklet gp | 31 | −0.9 (−1.4, −0.5) KG/M^2 | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | | SHED IT group | 34 | −1.5 (−2.0, −1.0) KG/M^2 | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | BMI (kg/m2) 6m | Prog info + Booklet gp | 31 | −1.1 (1.7, −0.5) | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | | SHED IT group | 34 | −1.6 (−2.2, −1.0) | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | Systolic blood pressure 3m | Prog info + Booklet gp | 31 | −8 (−12, −3) MM HG | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | | SHED IT group | 34 | −6 (−10, −1) MM HG | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | Systolic blood pressure 6m | Prog info + Booklet gp | 31 | −10 (−14, −6) | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | | SHED IT group | 34 | −10 (−14, −7) | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | Diastolic blood pressure 3m | Prog info + Booklet gp | 31 | −6 (−10, −2) MM HG | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | | SHED IT group | 34 | −4 (−8, −1) MM HG | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | Diastolic blood pressure 6m | Prog info + Booklet gp | 31 | −5 (−10, −2) | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | | SHED IT group | 34 | −6 (−11, −1) | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | Resting heart rate 3m | Prog info + Booklet gp | 31 | −7 (−11, −3) BPM | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | | SHED IT group | 34 | −9 (−12, −5) BPM | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | Resting heart rate 6m | Prog info + Booklet gp | 31 | −7 (−12, −3) BPM | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | | SHED IT group | 34 | −6 (−11, −2) BPM | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | Physical activity (mean steps/day) 3m | Prog info + Booklet gp | 31 | Went Up by: 976 (−12, 1,965) STEPS/DAY | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | | SHED IT group | 34 | Went Up by: 1,184 (234, 2,133) STEP/DAY | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | Physical activity (mean steps/day) 6m | Prog info + Booklet gp | 31 | Went Up by: 1,302 (241, 2,363) | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | | SHED IT group | 34 | Went Up by: 938 (−90, 1,966) | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | Energy intake (kJ/day) 3m | Prog info + Booklet gp | 31 | Went down by: −2,068 (−3,089, −1,047) KJ/DAY | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | | SHED IT group | 34 | Went down by: −3,195 (−4,159, −2,230) KJ/DAY | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | Energy intake (kJ/day) 6m | Prog info + Booklet gp | 31 | Went down by: −1,881 (−3,087, −676) KJ/DAY | | | | | | All differences statistically significant
Morgan, 2009^28^ Obesity | | SHED IT group | 34 | Went down by: −3,642 (−4,764, −2,521) KJ/DAY | | | | | | All differences statistically significant

BL = baseline, SD = standard deviation, , mos = months, wks = weeks, CHESS = Comprehensive Health Enhancement Support System, CES-D = Center for Epidemiologic Studies Depression Scale, CBT = cognitive behavior therapy, CACIS = Computer-Assisted Cognitive/Imagery System, FBG = Fasting blood glucose, TC = total cholesterol, TG = triglycerides, A1c = glycosylat ed hemoglobin

Reference List

1 Tarraga L, Boada M, Modinos G et al. A randomised pilot study to assess the efficacy of an interactive, multimedia tool of cognitive stimulation in Alzheimer's disease. J Neurol Neurosurg Psychiatry 2006; 77(10):1116–21.

2 Lorig KR, Ritter PL, Laurent DD, Plant K. The internet-based arthritis self-management program: a one-year randomized trial for patients with arthritis or fibromyalgia. Arthritis Rheum 2008; 59(7):1009–17.

3 Jan RL, Wang JY, Huang MC, Tseng SM, Su HJ, Liu LF. An internet-based interactive telemonitoring system for improving childhood asthma outcomes in Taiwan. Telemed J E Health 2007; 13(3):257–68.

4 Buhrman M, Faltenhag S, Strom L, Andersson G. Controlled trial of Internet-based treatment with telephone support for chronic back pain. Pain 2004; 111(3):368–77.

5 Gustafson DH, Hawkins R, Pingree S et al. Effect of computer support on younger women with breast cancer. J Gen Intern Med 2001; 16(7):435–45.

6 Gustafson DH, Hawkins R, Mctavish F et al. Internet-based interactive support for cancer patients: Are integrated systems better? 2008; 58(2):238–57.

7 Maslin AM, Baum M, Walker JS, A'Hern R, Prouse A. Using an interactive video disk in breast cancer patient support. Nurs Times 1998; 94(44):52–5.

8 Katz RC, Wertz RT. The efficacy of computer-provided reading treatment for chronic aphasic adults. J Speech Lang Hear Res 1997; 40(3):493–507.

9 Nguyen HQ, Donesky-Cuenco D, Wolpin S et al. Randomized controlled trial of an internet-based versus face-to-face dyspnea self-management program for patients with chronic obstructive pulmonary disease: pilot study. J Med Internet Res 2008; 10(2):e9.

10 Trautmann E, Kro?ner-Herwig B. Internet-based self-help training for children and adolescents with recurrent headache: A pilot study. 2008; 36(2):241–5.

11 Christensen H, Griffiths KM, Jorm AF. Delivering interventions for depression by using the internet: randomised controlled trial. BMJ 2004; 328(7434):265.

12 Hasson D, Anderberg UM, Theorell T, Arnetz BB. Psychophysiological effects of a web-based stress management system: a prospective, randomized controlled intervention study of IT and media workers. BMC Public Health 2005; 5:78.

13 Kerr J, Patrick K, Norman G et al. Randomized control trial of a behavioral intervention for overweight women: impact on depressive symptoms. Depress Anxiety 2008; 25(7):555–8.

14 March S, Spence SH, Donovan CL. The Efficacy of an Internet-Based Cognitive-Behavioral Therapy Intervention for Child Anxiety Disorders. J Pediatr Psychol 2008.

15 Orbach G, Lindsay S, Grey S. A randomised placebo-controlled trial of a self-help Internet-based intervention for test anxiety. Behav Res Ther 2007; 45(3):483–96.

16 Proudfoot J, Goldberg D, Mann A, Everitt B, Marks I, Gray JA. Computerized, interactive, multimedia cognitive-behavioural program for anxiety and depression in general practice. Psychol Med 2003; 33(2):217–27.

17 Spek V, Cuijpers P, Nyklicek I et al. One-year follow-up results of a randomized controlled clinical trial on internet-based cognitive behavioural therapy for subthreshold depression in people over 50 years. Psychol Med 2008; 38(5):635–9.

18 Homko CJ, Santamore WP, Whiteman V et al. Use of an internet-based telemedicine system to manage underserved women with gestational diabetes mellitus. Diabetes Technol Ther 2007; 9(3):297–306.

19 Tjam EY, Sherifali D, Steinacher N, Hett S. Physiological outcomes of an internet disease management program vs. in-person counselling: A randomized, controlled trial. 2006; 30(4):397–405.

20 Wise PH, Dowlatshahi DC, Farrant S. Effect of computer-based learning on diabetes knowledge and control. 1986; 9(5):504–8.

21 Adachi Y, Sato C, Yamatsu K, Ito S, Adachi K, Yamagami T. A randomized controlled trial on the long-term effects of a 1-month behavioral weight control program assisted by computer tailored advice. Behav Res Ther 2007; 45(3):459–70.

22 Hunter CM, Peterson AL, Alvarez LM et al. Weight management using the internet a randomized controlled trial. Am J Prev Med 2008; 34(2):119–26.

23 McConnon A, Kirk SF, Cockroft JE et al. The Internet for weight control in an obese sample: results of a randomised controlled trial. BMC Health Serv Res 2007; 7:206.

24 Tate DF, Jackvony EH, Wing RR. A randomized trial comparing human e-mail counseling, computer-automated tailored counseling, and no counseling in an Internet weight loss program. Arch Intern Med 2006; 166(15):1620–5.

25 Williamson DA, Walden HM, White MA et al. Two-year internet-based randomized controlled trial for weight loss in African-American girls. Obesity (Silver Spring) 2006; 14(7):1231–43.

26 Gustafson DH, Hawkins R, Boberg E et al. Impact of a patient-centered, computer-based health information/support system. Am J Prev Med 1999; 16(1):1–9.

27 Borckardt JJ, Younger J, Winkel J, Nash MR, Shaw D. The computer-assisted cognitive/imagery system for use in the management of pain. Pain Res Manag 2004; 9(3):157–62.

28 Morgan PJ, Lubans DR, Collins CE, Warren JM, Callister R. The SHED-IT Randomized Controlled Trial: Evaluation of an Internet-based Weight-loss Program for Men. Obesity (Silver Spring) 2009.

Evidence Table 38

Description of RCTs addressing the impact of CHI applications on economic outcomes (KQ1e)

Author, year | Consumer under study | CHI Application type | Location | Year data collected/duration of intervention | Inclusion criteria | Exclusion criteria | Control | Intervention | Jadad score
Asthma
Joseph, 2007^1^ | Individual interested in their own health | Interactive consumer website | Remote location: school | NS | 9–11 grade, Current asthma | NS | Generic asthma website | Tailored website | 2.5
Breast cervical prostate and laryngeal cancer
Jones, 1999^2^ | Individual interested in their own health care | Interactive consumer website | Clinician office | December 1996–December 1997/NS | Breast, laryngeal, prostate, Cervical cancer patients receiving care at oncology center | Receiving palliative treatment, no knowledge of diagnosis, visual or mental handicap, severe pain | Booklet information | General computer information Personalized computer information | 1.5
Obesity
McConnon, 2007^3^ | Individual interested in their own health care | Interactive consumer website | Home/residence | NS | 18 – 65 yr, BMI 30 or more, able to access internet at least 1 time a week, able to read and write English | NS | Usual care | Internet group | 1

NS = Not specified, BMI = Body mass index, Yr = year

Reference List

1 Joseph CL, Peterson E, Havstad S et al. A web-based, tailored asthma management program for urban African-American high school students. Am J Respir Crit Care Med 2007; 175(9):888–95.

2 Jones R, Pearson J, McGregor S et al. Randomised trial of personalised computer based information for cancer patients. BMJ 1999; 319(7219):1241–7.

3 McConnon A, Kirk SF, Cockroft JE et al. The Internet for weight control in an obese sample: results of a randomised controlled trial. BMC Health Serv Res 2007; 7:206.

Evidence Table 39

Description of consumer characteristics in studies addressing the impact of CHI applications on economic outcomes (KQ1e)

Author, year | Control Intervention | Age | Race, n(%) | Income | Education, n(%) | SES | Gender, n (%) | Other characteristics
Asthma
Joseph, 2007^1^ | Generic asthma website | Mean, 15.3 SD, 1 | NS | NA | High school students | NS | F, 199 (63.4) | Smoking status: ≥ 2 per day, 15 (5.2)
Joseph, 2007^1^ | Tailored website | Mean, 15.3 SD, 1 | NS | NA | High school students | NS | F, 199 (63.4) | Smoking status: ≥ 2 per day, 15 (5.2)
Cancer: breast, lung, prostate and esophageal
Jones, 1999^2^ | Booklet information | No baseline participant characteristics were provided
Jones, 1999^2^ | General computer information | No baseline participant characteristics were provided
Jones, 1999^2^ | Personal computer information | No baseline participant characteristics were provided
Obesity
McConnon, 2007^3^ | “usual care”. Participants randomized to the usual care group were advised to continue with their usual approach to weight loss and were given a small amount of printed information at baseline, reflecting the type of information available within primary care. | Mean, 47.4 | NS | NS | NS | NS | NS | Weight (kg): mean, 94.9 kg BMI: mean, 34.4 Quality of Life (Euro QoL): mean, 61.5 Physical Activity (Baecke): mean, 6.7
McConnon, 2007^3^ | Internet group | Mean, 48.1 | NS | NS | NS | NS | NS | Weight (kg): mean, 97.5 kg BMI: mean, 34.35 Quality of Life (EuroQoL): mean, 70 Physical Activity (Baecke): mean, 6.8

* Only “all participants” data was provided in this paper with a notation that there were no differences between the treatment and control groups

NS = not specified, SD = standard deviation, BMI = body mass index, kg = kilogram, SES= Socioeconomic Status, NA = Not Applicable, QoL = quality of Life

Reference List

1 Joseph CL, Peterson E, Havstad S et al. A web-based, tailored asthma management program for urban African-American high school students. Am J Respir Crit Care Med 2007; 175(9):888–95.

2 Jones R, Pearson J, McGregor S et al. Randomised trial of personalised computer based information for cancer patients. BMJ 1999; 319(7219):1241–7.

3 McConnon A, Kirk SF, Cockroft JE et al. The Internet for weight control in an obese sample: results of a randomised controlled trial. BMC Health Serv Res 2007; 7:206.

Evidence Table 40

All outcomes in studies addressing the impact of CHI applications on economic outcomes (KQ1e)

Author, year | Outcome | Control Intervention | n | Measure at BL | Measure at final time point, define
Asthma
Joseph, 2007^1^ | Cost of program delivery | Control | 152 | No baseline measure of cost | 12 months: no cost estimate for control group
Joseph, 2007^1^ | Cost of program delivery | Treatment | 162 | No baseline measure of cost | 12 months: cost of referral coordinator, $6.66/per treatment student
Cancer: breast cervical prostate and laryngeal cancer
Jones, 1999^2^ | Cost of the computer information system—Manual extraction of Patient data | Control: books alone | 162 | No baseline measure of cost
Jones, 1999^2^ | Cost of the computer information system—Manual extraction of Patient data | General computer information | 143 | No baseline measure of cost
Jones, 1999^2^ | Cost of the computer information system—Manual extraction of Patient data | Tailored computer information | 162 | No baseline measure of cost | 9x the cost of a general information system
Jones, 1999^2^ | Cost of the computer information system—use of electronic patient record | Control: books alone | 162 | No baseline measure of cost
Jones, 1999^2^ | Cost of the computer information system—use of electronic patient record | General computer information | 143 | No baseline measure of cost
Jones, 1999^2^ | Cost of the computer information system—use of electronic patient record | Tailored computer information | 162 | No baseline measure of cost | No difference in cost between general and tailored systems
Jones, 1999^2^ | Materials cost | Control: books alone | 162 | No baseline measure of cost | £7/patient
Jones, 1999^2^ | Materials cost | General computer information | 143 | No baseline measure of cost | £2.8/patient
Jones, 1999^2^ | Materials cost | Tailored computer information | 162 | No baseline measure of cost | NS
Obesity
McConnon, 2007^3^ | Total costs | Control | 110 | No baseline costs reported | £276.12
McConnon, 2007^3^ | Total costs | Website (internet group) | 111 | No baseline costs reported | £992.40^*^
McConnon, 2007^3^ | Incremental cost-effectiveness | Control | 110 | No baseline costs reported | NS
McConnon, 2007^3^ | Incremental cost-effectiveness | Website (internet group) | 111 | No baseline costs reported | £39,248/QALY

* Difference in cost is due to the cost of developing the website; when this fixed cost was removes; total costs were lower in the intervention group (actual results not presented).

BL = baseline, NS = not specified, QALY = quality-adjusted life year, $ = United States Dollars

Reference List

1 Joseph CL, Peterson E, Havstad S et al. A web-based, tailored asthma management program for urban African-American high school students. Am J Respir Crit Care Med 2007; 175(9):888–95.

2 Jones R, Pearson J, McGregor S et al. Randomised trial of personalised computer based information for cancer patients. BMJ 1999; 319(7219):1241–7.

3 McConnon A, Kirk SF, Cockroft JE et al. The Internet for weight control in an obese sample: results of a randomised controlled trial. BMC Health Serv Res 2007; 7:206.

Evidence Table 41

Description of all study designs addressing barriers KQ 2

Author, year | Design | Barrier type | TARGET Condition | Consumer | Application | Location | Year/duration | Inclusion / Exclusion | Control/Interventions
Simon, 2008^1^ | Survey/interview | User level | Breast cancer | Individuals interested in their own health care , women getting mammogram | Interactive electronic tool | Clinician office | 2007/NS | Female scheduled to get a mammogram | No control group/ D Survey respondents
Cimino, 2001^2^ | Survey (cross-sectional) | System level User level | Usage study of general med group | Individuals interested in their own health care | Access to patient records with tailored feedback | NS | 1999/NS | | No control group
Keselman, 2007^3^ | Survey | System level User level | Multiple condition | Individuals interested in their own health care | Interactive consumer website | NS | 2006 | Who viewed their paper or electronic health records within the past year | No control group
Shaw, 2008^4^ | Applicability of a C-SHIP model to discern why people with cancer seek online information to cope with disease | User level | Breast cancer | Individuals interested in their own health care | Interactive consumer website | NS | May 2001 | Women participants were at or below 250% of the federal poverty level resided within one of 56 rural Wisconsin counties (as defined by the Office of Management and Budget criteria) within one year of diagnosis of breast cancer or had metastatic breast cancer not homeless able to read and understand an informed consent letter | No control group/CHESS users
Nijland, 2008^5^ | | System level User Level | Design of the Internet-based applications for self-care | Individuals interested in their own health care, non-medical caregiver | Interactive consumer website | Home/residence workplace | NS | At least 18 yr old Dutch speaking had experience with using one of the Internet based applications | No control group
Morak, 2008^6^ | Pilot | User level | Obesity | Individuals interested in their own health care | Interactive consumer website | Clinician office | NS | | No control group
Steele, 2007^7^ | RCT | System level | Diet/exercise/physical activity NOT obesity | Individuals interested in their own health care | Interactive consumer website | Local community of Rock Hampton, Queensland | 12 weeks | More than 18 years old Both male and female Functionally mobile more than 10 min Inactive Access to internet Singed informed consent. Less than 18 years Functionally immobile more than 10 min Active No access to internet Did not signed informed consent | No control group/Face to face n:52, Both face to face and internet n:51, Internet only:56
Wangberg, 2008^8^ | RCT | User level | Diabetes | Individuals interested in their own health care | Interactive consumer website | NS | NS | 17–67 yr Type I or II diabetes access to the internet | Low self-efficacy
Lober, 2006^9^ | Survey | User level | Computer literacy Computer anxiety Cognitive impairment Health literacy Physical impairment | Individuals interested in their own health care | Patient kiosk | Home/residence Remote location, common computer area | 8 months | Resident at publicly subsidized housing project | No control group
Stock, 2006^10^ | Within-subject design | System level | Usability | Individuals interested in their own health care | Palmtop computer | NS | NS | 18–54 yr both male and female intellectual disabilities vision, hearing and motor skills to interact with palmtop | No control group/all subjects
Mangunkusumo, 2007^11^ | RCT | System level | Diet/exercise/physical activity NOT obesity | Individuals interested in their own health care, student--with parental consent | Internet site | Remote location, at a secondary school | NS
Ferney, 2006^12^ | Qualitative; semi-structured interview | System level | Diet/exercise/physical activity NOT obesity | Individuals interested in their own health care | Interactive consumer website, | Unspecified location of a study group | NS | | No control group
Temesgen, 2006^13^ | Survey | System level User level | HIV/AIDS | Individuals interested in their own health care | Interactive consumer website, | Home/residence | 6 months | HIV positive | No control/Use of CHESS intervention
Owen, 2004^14^ | Survey | User level | Breast cancer | Individuals interested in their own health care | Interactive consumer website, | Clinician office | 1999/NS | Appointment at Dept of Hematology/Oncology at the University of Alabama at Birmingham Comprehensive Cancer Center Histologicaly confirmed breast cancer | No control group
Lahdenpera, 2000^15^ | Interviewed before use of IT application | User level | Hypertension | Individuals interested in their own health care | Personal monitoring device | Clinician office | Between summer 1997 and Autumn 1998 | 16–64 yr, Hypertension for one year or less Hypertension medication for one year or less or none Three successive blood pressure readings exceeded 140/90 mm Hg | No control group/Study group
Weber, 1998^16^ | | User level | DSM-III-R psychiatric disorders | Individuals interested in their own health care | Interactive self assessment | NS | NS | Mixed DSM-III-R psychiatric disorders and healthy volunteers hospitalized for psych disorders | Healthy group/Patients
Jenkinson, 1998^17^ | Qualitative study | User level | Prostate cancer | Individuals interested in their own health care | Interactive consumer website, | Clinician office | NS | Newly diagnosed (1–12 months) English speaking localized prostate cancer
Paperny, 1997^18^ | Survey after use | User level | HIV/AIDS and substance abuse | Individuals interested in their own health care, Youth at risk | Interactive consumer website, | Clinician office Public Health Fairs, school, detention facility, runaway shelter and a youth corrections facility | NS | "Teens" | No control group/Public School, Medical Clinics, Detainees and runaways
McTavish, 1994^19^ | Qualitative | User level | Breast cancer | Individuals interested in their own health care | Interactive consumer website | Home/residence | 1993 and 1994 | Stage 1 or 2 breast cancer | No control group/Users of CHESS program in Chicago Pilot Study
Cavan, 2003^20^ | Pilot trial | User level | Diabetes | Individuals interested in their own health care | Interactive consumer website | Home/residence | NS | 29–61 yr | No control group/Patient with type 1 diabetes
Feil, 2000^21^ | A study in a primary care setting | User level | Diabetes | Individuals interested in their own health care | Interactive consumer website | Home/residence | 1 yr | 40–75 yr Female Have current internet access Type 2 diabetes Healthy Diagnosed at least 1 year Not moving or staying in the area Can read or write English Under 40 or over 75 years Male Current internet access No type 2 diabetes Incapacitated or too ill Diagnosed less than 1 year Moving or not in area Can’t read or write English | No control group
Zeman, 2006^22^ | A study on PDA implementation problem | System level User level | Mental health | NS | Disease specific sensor | Clinician office | NS | | No control group
Bryce, 2008^23^ | Combination of qualitative methods and quantitative methods | User level System level | Diabetes | Individuals interested in their own health care | Web-Based Portal for Management of Diabetes | | Between August 2004 and January 2005 | participate were over the age of 21years, Were English-speaking, received a diagnosis of type 1 or type 2 diabetes mellitus, Agreed to attend a focus group session and complete a survey
Leslie, 2005^24^ | RCT | User level | Physical Activity/Diet/Obesity | Individuals interested in their own health care | Interactive consumer website | NS
Ferrer-Roca, 2004^25^ | mobile phone text messaging (short message service; SMS) for diabetes management | User level System level | Diabetes | Individuals interested in their own health care | mobile phone text messaging | Home/residence | 8 months | All patients had a diagnosis of diabetes and were aged 18–75 years. Patients had to have their own personal mobile phone, or have access to one belonging to a relative.
Lenert, 2003^26^ | Pilot | User level | Smoking Cessation | Individuals interested in their own health care | Interactive consumer website | NS
Kressig, 2002^27^ | To determine if older adults are capable and willing to interact with a computerized exercise promotion interface | User level | Physical Activity/Diet/Obesity | Individuals interested in their own health care | Interactive consumer website | | | participants if they were 60 years of age and older and without medical contraindication for exercise.
Brug, 1998^28^ | RCT | User level | Physical Activity/Diet/Obesity | Individuals interested in their own health care | computer-generated tailored poster | | | | individualized computer-generated nutrition information
Boberg, 1995^29^ | Survey | User level | HIV/AIDS | Individuals interested in their own health care | Interactive consumer website (CHESS) | Home/residence | | people living with AIDS/HIV infection | CHESS
Shaw, 2001^30^ | RCT | System level | All cancer | Individuals interested in their own health care | | Physician office | January 1, 1996 to August 1, 1997 | Eligible patients were 18 to 80 years old, spoke English, had never had a colonoscopy, and were not scheduled to receive. | Interactive Computer-assisted Instruction Program
Strecher, 1994^31^ | RCT | User level | Smoking cessation | Individuals interested in their own health care | computer-generated tailored letter | Home/residence | During March and April 1990 | Eligible patients were 40 to 65 years old Had seen a family physician in the practice no more than 6 months before being interviewed, had telephones with available and working numbers | Generic health letter/Tailored health letter

NS = not specified, CHESS = Comprehensive Health Enhancement Support System, yr = year, RCT = randomized controlled trial, CHESS = Comprehensive Health Enhancement Support System

Reference List

1 Simon C, Acheson L, Burant C et al. Patient interest in recording family histories of cancer via the Internet. Genet Med 2008; 10(12):895–902.

2 Cimino JJ, Patel VL, Kushniruk AW. What do patients do with access to their medical records? Stud Health Technol Inform 2001; 84(Pt 2):1440–4.

3 Keselman A, Slaughter L, Smith CA et al. Towards consumer-friendly PHRs: patients' experience with reviewing their health records. AMIA Annu Symp Proc 2007; 399–403.

4 Shaw BR, Dubenske LL, Han JY et al. Antecedent characteristics of online cancer information seeking among rural breast cancer patients: an application of the Cognitive-Social Health Information Processing (C-SHIP) model. J Health Commun 2008; 13(4):389–408.

5 Nijland N, van Gemert-Pijnen J, Boer H, Steehouder MF, Seydel ER. Evaluation of internet-based technology for supporting self-care: problems encountered by patients and caregivers when using self-care applications. J Med Internet Res 2008; 10(2):e13.

6 Morak J, Schindler K, Goerzer E et al. A pilot study of mobile phone-based therapy for obese patients. J Telemed Telecare 2008; 14(3):147–9.

7 Steele R, Mummery KW, Dwyer T. Development and process evaluation of an internet-based physical activity behaviour change program. Patient Educ Couns 2007; 67(1–2):127–36.

8 Wangberg SC. An Internet-based diabetes self-care intervention tailored to self-efficacy. Health Educ Res 2008; 23(1):170–9.

9 Lober WB, Zierler B, Herbaugh A et al. Barriers to the use of a personal health record by an elderly population. AMIA Annu Symp Proc 2006; 514–8.

10 Stock SE, Davies DK, Davies KR, Wehmeyer ML. Evaluation of an application for making palmtop computers accessible to individuals with intellectual disabilities. J Intellect Dev Disabil 2006; 31(1):39–46.

11 Mangunkusumo R, Brug J, Duisterhout J, de Koning H, Raat H. Feasibility, acceptability, and quality of Internet-administered adolescent health promotion in a preventive-care setting. Health Educ Res 2007; 22(1):1–13.

12 Ferney SL, Marshall AL. Website physical activity interventions: preferences of potential users. Health Educ Res 2006; 21(4):560–6.

13 Temesgen Z, Knappe-Langworthy JE, St Marie MM, Smith BA, Dierkhising RA. Comprehensive Health Enhancement Support System (CHESS) for people with HIV infection. AIDS Behav 2006; 10(1):35–40.

14 Owen JE, Klapow JC, Roth DL, Nabell L, Tucker DC. Improving the effectiveness of adjuvant psychological treatment for women with breast cancer: the feasibility of providing online support. Psychooncology 2004; 13(4):281–92.

15 Lahdenpera TS, Kyngas HA. Patients' views about information technology in the treatment of hypertension. J Telemed Telecare 2000; 6(2):108–13.

16 Weber B, Fritze J, Schneider B, Simminger D, Maurer K. Computerized self-assessment in psychiatric in-patients: acceptability, feasibility and influence of computer attitude. Acta Psychiatr Scand 1998; 98(2):140–5.

17 Jenkinson J, Wilson-Pauwels L, Jewett MA, Woolridge N. Development of a hypermedia program designed to assist patients with localized prostate cancer in making treatment decisions. J Biocommun 1998; 25(2):2–11.

18 Paperny DM. Computerized health assessment and education for adolescent HIV and STD prevention in health care settings and schools. Health Educ Behav 1997; 24(1):54–70.

19 McTavish FM, Gustafson DH, Owens BH et al. CHESS: An interactive computer system for women with breast cancer piloted with an under-served population. Proc Annu Symp Comput Appl Med Care 1994; 599–603.

20 Cavan DA, Everett J, Plougmann S, Hejlesen OK. Use of the Internet to optimize self-management of type 1 diabetes: preliminary experience with DiasNet. 2003; 9 Suppl 1.

21 Feil EG, Glasgow RE, Boles S, McKay HG. Who participates in internet-based self-management programs? A study among novice computer users in a primary care setting. 2000; 26(5):806–11.

22 Zeman L, Johnson D, Arfken C, Smith T, Opoku P. Lessons learned: challenges implementing a personal digital assistant (PDA) to assess behavioral health in primary care. Families, Systems & Health: The Journal of Collaborative Family HealthCare 2006; 24(3):286–98.

23 Bryce CL, Zickmund S, Hess R et al. Value versus user fees: perspectives of patients before and after using a web-based portal for management of diabetes. Telemed J E Health 2008; 14(10):1035–43.

24 Leslie E, Marshall AL, Owen N, Bauman A. Engagement and retention of participants in a physical activity website. 2005; 40(1):54–9.

25 Ferrer-Roca O, C+írdenas A, Diaz-Cardama A, Pulido P. Mobile phone text messaging in the management of diabetes. 2004; 10(5):282–5.

26 Lenert L, Mu+_oz RF, Stoddard J et al. Design and pilot evaluation of an internet smoking cessation program. 2003; 10(1):16–20.

27 Kressig RW, Echt KV. Exercise prescribing: Computer application in older adults. 2002; 42(2):273–7.

28 Brug J, Glanz K, Van Assema P, Kok G, Van Breukelen GJP. The Impact of Computer-Tailored Feedback and Iterative Feedback on Fat, Fruit, and Vegetable Intake. 1998; 25(4):517–31.

29 Boberg EW, Gustafson DH, Hawkins RP et al. Development, acceptance, and use patterns of a computer-based education and social support system for people living with AIDS/HIV infection. 1995; 11(2):289–311.

30 Shaw MJ, Beebe TJ, Tomshine PA, Adlis SA, Cass OW. A randomized, controlled trial of interactive, multimedia software for patient colonoscopy education. 2001; 32(2):142–7.

31 Strecher VJ, Kreuter M, Den Boer D-J, Kobrin S, Hospers HJ, Skinner CS. The effects of computer-tailored smoking cessation messages in family practice settings. 1994; 39(3):262–70.

Evidence Table 42

Characteristics of consumers in studies addressing barriers to CHI applications

Author, year | Control Interventions | Age | Race, n(%) | Income | Education, n(%) | SES | Gender, n(%) | Marital status | Other characteristics
Simon, 2008^1^ | | Mean, 56.68 range, 36–89 SD, 11.22 | AA: 26 (40) Caucasian: 39 (60) | USD <20,000, 20 (31) 20,000–50,000, 11 (17) >50,000, 29 (45) | <8 yr, 22 (34) 8–12 yr, 27 (41) 12–16 yr, 16 (25) | NS | | NS | Internet access: Use, 52 (80), computer at home, 52 (80) internet at home, 46 (71) Frequency on-line: Daily, 27 (42) several times a week, 11 (17) once a week or less, 14 (22) never, 13 (20)
Cimino, 2001^2^ | No control group | NS | NS | NS | NS | | | | NS
Keselman, 2007^3^ | No control group | | White non-Hispanic, 95 API, 2 Other, 5 | | 8–12 yr, 9 12–16 yr, 48 >16 yr, 39 | | M, 14 F, 89
Shaw, 2008^4^ | CHESS users | Mean, 51.81 SD, 12.11 | White non-Hispanic, 144(100) | NS | Some junior high, 1 (0.7) Some high school, 12 (8.3) High school degree, 48 (33.3) Some college, 39 (27.1) | NS | | NS | Stage of cancer: Early stage (stage 0, 1, 2), 97 (67.4)
Nijland, 2008^5^ | No control group | NS | NS | NS | NS | NS | | NS | NS
Morak, 2008^6^ | Obese patient with mobile phone | Mean, 48 range, 24–71 | NS | NS | NS | NS | | NS | BMI: mean, 35.6 SD, 5.2
Steele, 2007^7^ | Face to face n,52 | Mean, 38.3 SD, 12.6 | NS | NS | NS | NS | | NS | BMI: mean, 31.59 SD, 7.47 Physical activity: mean, 76.4 SD, 93 H/O internet use : <6 months, 9(17.3) 6–12 months=1 (1.9) 1–1.5 yr, 5 (9.6) >2 yr, 6 (11.5)
Steele, 2007^7^ | Intervention | Mean, 39.3 SD, 14.4 | NS | NS | NS | | M, 11 (21.6) F, 40 (78.4) | NS | BMI: mean, 31.63 SD, 7.9 Physical activity: mean, 80.8SD, 96.8 H/O internet use :<6 months, 1(2.0) – 12 months, (3.9) 1–1.5 yr, 3 (5.9) >2 yr, 7 (13.7) H/O internet use : <6 months, 1(2.0) 6–12 months, 2 (3.9) 1–1.5 yr,3 (5.9) >2 years,7 (13.7)
Wangberg, 2008^8^ | No control group, | Mean, 37.3 range, 33.2–41.4 | NS | NS | NS | NS | F, (63) | NS | Type I Diabetes:72 Insulin use:78 HbA1C:7.7
Wangberg, 2008^8^ | High self-efficacy | Mean, 42.9 range, 38.0–47.9 | NS | NS | 8–12 yr, (8) | | F,(50) | NS | Type I Diabetes:(50) Insulin use: (71)
Lober, 2006^9^ | All participants | Mean, 69 range, 49–92 | NS | NS | NS | NS | F,(82) | NS
Stock, 2006^10^ | All subjects n,32 | Mean, 30.8 range, 18–54 SD, 12.1 | NS | NS | NS | NS | | NS
Mangunkusumo, 2007^11^ | Intervention | Mean, 15 range, 13–17 | Dutch, (76.5) Other, (23.5) | | Lower secondary/Vocational, (59.1) International secondary, (18.6) Upper secondary, (22.3) | NS | M,(43.9) | NS
Ferney, 2006^12^ | Define, low self-efficacy | NS | NS | NS | NS | NS | | NS | NS
Ferney, 2006^12^ | Study group | 18–44 yr, 16 45–65 yr, 24 | NS | NS | 12–16 yr, 23 | Employed | | Married/partner: 31 | Physical activity: sufficient, 24
Temesgen, 2006^13^ | | Range, 30–59 | White non-Hispanic, 7(87.5) NS, 1, (12.5) | | All finished high school | | | NS | Employment: over half were employed
Owen, 2004^14^ | Intervention | Mean, 53.9 | White non-Hispanic, (84) Black non-Hispanic, (16) | USD median, 45,000 | Yr mean, 14 | | | NS | Clinical Stage (%): 1:28.7 2:40.1 3:11.5 4:19.7
Lahdenpera, 2000^15^ | Intervention | Mean, 46 range, 32–63 | NS | NS | NS | Low, 13 higher income, 14 | M, 9 (42.9) F, 12 (57.1) | NS
Weber, 1998^16^ | Comparison | Mean, 30.5 SD, 7.8 | NS | NS | NS | NS | | NS | NS
Weber, 1998^16^ | Patients | Mean, 50.7 SD, 19.4 | NS | NS | NS | NS | | NS
Jenkinson, 1998^17^ | No control group | NS | NS | NS | NS | NS | | NS | NS
Paperny, 1997^18^ | Public School | Mean, 15.5 range, 15- | NS | NS | NS | NS | F, (51) | NS
Paperny, 1997^18^ | Medical clinics/health fairs | Range, 13–19 | NS | NS | NS | | | NS
Paperny, 1997^18^ | Detainees and runaways | Mean, 15.4 range 13- | NS | NS | NS | NS | | NS | NS
McTavish, 1994^19^ | Intervention | Range, 36–66 | NS | NS | NS | NS | | NS | Computer experience: Any prior:
Cavan, 2003^20^ | Patients with type 1 diabetes n,6 | Mean, 36 range, 29–61 | NS | NS | NS | NS | | NS
Feil, 2000^21^ | Define, healthy group | NS | NS | NS | NS | NS | | NS | NS
Feil, 2000^21^ | Participants | Mean, 59.2 SD, 6.9 | NS | NS | NS | NS | | NS | Own computer,53.1 Familiar with computers, 1.7 (0.68) Years diagnosed, 9.5 (7.7)
Zeman, 2006^22^ | Participants | NS | Black non-Hispanic, (83) | USD <30,000, ( 40) | 12–16 yr, (65) | NS | | NS | NS
Bryce, 2008^23^ | Preportal group | mean, 53 SD, 13 | Nonwhite, 7(33) | | High school graduate 6 (29) Some college 7 (33) College graduate 2 (10) Postgraduate degree 6 (29) | | | | Owns a computer (%) 13 (62) Type 1 diabetes (%) 1 (5)
Bryce, 2008^23^ | portal-user group | mean, 55 SD, 11 | Nonwhite, 4(22) | | High school graduate 1 (6) Some college 5 (28) College graduate 4(22) Postgraduate degree 8 (44) | | | | Owns a computer (%) 17 (94) Type 1 diabetes (%) 2(11)
Leslie, 2005^24^ | Print Website-delivered intervention | mean age of 43 years | | | 72% had completed secondary school or higher
Ferrer-Roca, 2004^25^ | Participants | range 18–75
Lenert, 2003^26^ | Participants | mean, 46 yrs | Caucasian, (84) | | some college education (75) | | F (78) | | 15 of 34 had no or very little computer experience
Kressig, 2002^27^ | Participants | mean, 70.4 SD, 6.9 range, 60–87 years | | | some college education or more, 33 | | M 17 F 17
Brug, 1998^28^ | ControlD Intervention | mean, 44 SD, 14 | | | college degree (42) | | F (82)
Boberg, 1995^29^ | CHESS (the Comprehensive Health Enhancement Support System) | mean, 34.9 yrs | White, (78.1) Non-White, (21.9) | Average $15,010 | Average 13.9 years | No (47.8) Yes (52.2) | M (82.8) F 17.2 | Living Status Alone(24.8) Not alone (75.2) | AI DS Stage Symptomatic (65.5) Nonsymptomatic (34.5)
Shaw, 2001^30^ | Interactive Computer-assisted Instruction Program | mean, 53.9yrs SD, 13.83yrs | | | College degree, (58) | | F (56) | | some exposure to computers (88)
Strecher, 1994^31^ | Control Intervention | mean, 49.5yrs | | | | | F (67.7)

AA = African-American, Yr = year, NS = Not specified, SD = standard deviation, SES = Socioeconomic Status, M = Male, F = Female, USD = United States Dollar C = Caucasian, BMI = body mass index, API = Asian/Pacific Islander

Reference List

1 Simon C, Acheson L, Burant C et al. Patient interest in recording family histories of cancer via the Internet. Genet Med 2008; 10(12):895–902.

2 Cimino JJ, Patel VL, Kushniruk AW. What do patients do with access to their medical records? Stud Health Technol Inform 2001; 84(Pt 2):1440–4.

3 Keselman A, Slaughter L, Smith CA et al. Towards consumer-friendly PHRs: patients’ experience with reviewing their health records. AMIA Annu Symp Proc 2007; 399–403.

4 Shaw BR, Dubenske LL, Han JY et al. Antecedent characteristics of online cancer information seeking among rural breast cancer patients: an application of the Cognitive-Social Health Information Processing (C-SHIP) model. J Health Commun 2008; 13(4):389–408.

5 Nijland N, van Gemert-Pijnen J, Boer H, Steehouder MF, Seydel ER. Evaluation of internet-based technology for supporting self-care: problems encountered by patients and caregivers when using self-care applications. J Med Internet Res 2008; 10(2):e13.

6 Morak J, Schindler K, Goerzer E et al. A pilot study of mobile phone-based therapy for obese patients. J Telemed Telecare 2008; 14(3):147–9.

7 Steele R, Mummery KW, Dwyer T. Development and process evaluation of an internet-based physical activity behaviour change program. Patient Educ Couns 2007; 67(1–2):127–36.

8 Wangberg SC. An Internet-based diabetes self-care intervention tailored to self-efficacy. Health Educ Res 2008; 23(1):170–9.

9 Lober WB, Zierler B, Herbaugh A et al. Barriers to the use of a personal health record by an elderly population. AMIA Annu Symp Proc 2006; 514–8.

10 Stock SE, Davies DK, Davies KR, Wehmeyer ML. Evaluation of an application for making palmtop computers accessible to individuals with intellectual disabilities. J Intellect Dev Disabil 2006; 31(1):39–46.

11 Mangunkusumo R, Brug J, Duisterhout J, de Koning H, Raat H. Feasibility, acceptability, and quality of Internet-administered adolescent health promotion in a preventive-care setting. Health Educ Res 2007; 22(1):1–13.

12 Ferney SL, Marshall AL. Website physical activity interventions: preferences of potential users. Health Educ Res 2006; 21(4):560–6.

13 Temesgen Z, Knappe-Langworthy JE, St Marie MM, Smith BA, Dierkhising RA. Comprehensive Health Enhancement Support System (CHESS) for people with HIV infection. AIDS Behav 2006; 10(1):35–40.

14 Owen JE, Klapow JC, Roth DL, Nabell L, Tucker DC. Improving the effectiveness of adjuvant psychological treatment for women with breast cancer: the feasibility of providing online support. Psychooncology 2004; 13(4):281–92.

15 Lahdenpera TS, Kyngas HA. Patients’ views about information technology in the treatment of hypertension. J Telemed Telecare 2000; 6(2):108–13.

16 Weber B, Fritze J, Schneider B, Simminger D, Maurer K. Computerized self-assessment in psychiatric in-patients: acceptability, feasibility and influence of computer attitude. Acta Psychiatr Scand 1998; 98(2):140–5.

17 Jenkinson J, Wilson-Pauwels L, Jewett MA, Woolridge N. Development of a hypermedia program designed to assist patients with localized prostate cancer in making treatment decisions. J Biocommun 1998; 25(2):2–11.

18 Paperny DM. Computerized health assessment and education for adolescent HIV and STD prevention in health care settings and schools. Health Educ Behav 1997; 24(1):54–70.

19 McTavish FM, Gustafson DH, Owens BH et al. CHESS: An interactive computer system for women with breast cancer piloted with an under-served population. Proc Annu Symp Comput Appl Med Care 1994; 599–603.

20 Cavan DA, Everett J, Plougmann S, Hejlesen OK. Use of the Internet to optimize self-management of type 1 diabetes: preliminary experience with DiasNet. 2003; 9 Suppl 1.

21 Feil EG, Glasgow RE, Boles S, McKay HG. Who participates in internet-based self-management programs? A study among novice computer users in a primary care setting. 2000; 26(5):806–11.

22 Zeman L, Johnson D, Arfken C, Smith T, Opoku P. Lessons learned: challenges implementing a personal digital assistant (PDA) to assess behavioral health in primary care. Families, Systems & Health: The Journal of Collaborative Family HealthCare 2006; 24(3):286–98.

23 Bryce CL, Zickmund S, Hess R et al. Value versus user fees: perspectives of patients before and after using a web-based portal for management of diabetes. Telemed J E Health 2008; 14(10):1035–43.

24 Leslie E, Marshall AL, Owen N, Bauman A. Engagement and retention of participants in a physical activity website. 2005; 40(1):54–9.

25 Ferrer-Roca O, C+írdenas A, Diaz-Cardama A, Pulido P. Mobile phone text messaging in the management of diabetes. 2004; 10(5):282–5.

26 Lenert L, Mu+_oz RF, Stoddard J et al. Design and pilot evaluation of an internet smoking cessation program. 2003; 10(1):16–20.

27 Kressig RW, Echt KV. Exercise prescribing: Computer application in older adults. 2002; 42(2):273–7.

28 Brug J, Glanz K, Van Assema P, Kok G, Van Breukelen GJP. The Impact of Computer-Tailored Feedback and Iterative Feedback on Fat, Fruit, and Vegetable Intake. 1998; 25(4):517–31.

29 Boberg EW, Gustafson DH, Hawkins RP et al. Development, acceptance, and use patterns of a computer-based education and social support system for people living with AIDS/HIV infection. 1995; 11(2):289–311.

30 Shaw MJ, Beebe TJ, Tomshine PA, Adlis SA, Cass OW. A randomized, controlled trial of interactive, multimedia software for patient colonoscopy education. 2001; 32(2):142–7.

31 Strecher VJ, Kreuter M, Den Boer D-J, Kobrin S, Hospers HJ, Skinner CS. The effects of computer-tailored smoking cessation messages in family practice settings. 1994; 39(3):262–70.

Evidence table 43

All barriers identified to the use of CHI applications

Author, year | Barriers and target conditions | DATA collection method | Comment | Conclusions
Simon, 2008^1^ | Barrier type: user-level barriers Other: privacy Barrier under study: CHI application use too time consuming; confidentiality/privacy; control of information; lack of technical infrastructure. Patient preferences: not comfortable giving history to provider in person either; did not need a risk assessment; using an electronic tool to record data as opposed to paper and pen Other important barriers identified during study: knowledge literacy. Target condition: breast cancer; any form of familial cancer. Other: family history of cancer | Non-validated survey | Respondents also cited incentives to use an electronic tool for recording family h/o cancer: save time, help researchers and help speed research for people “in their culture”, to pass on to family, something new. | This finding suggests that, in this population, computer literacy and Internet access per se may not be the most important predictors of whether mammogram patients are or are not interested in using an online computer program to record their FHC. As a result, a challenge of research on the clinical utility of electronic tools for recording FHC will be to characterize the contexts in which they are deployed, with regard to what users (and nonusers) understand about security and privacy of online information, and the means whereby the computer tool is integrated into clinical care or research.
Cimino, 2001^2^ | Barrier type: user-level barriers; systems-level barriers. Barrier under study: application usability; incompatibility with current care; knowledge literacy; lack of technical infrastructure. Target condition: personal health record | Non-validated survey Qualitative | | use of the system enhanced patient understanding of their condition and improved patient-physician communication
Keselman, 2007^3^ | Barrier type: user-level barriers; systems-level barriers. Barrier under study: application usability; confidentiality/privacy; control of information; knowledge literacy; language. Target condition: multiple -patients' information and comprehension needs related to their medical records. | Non-validated survey | | the present study suggests that work in the area of machine translation into consumer friendly forms, user-friendly presentation of difficult concepts and multiple-view representation have the promise of improving health records review experience for lay readers
Shaw, 2008^4^ | Barrier type: user-level barriers Barrier under study: cultural; knowledge literacy. Patient preferences: beliefs affect goals & values; well being (functional and emotional) Target condition: breast cancer. | Validated survey | C-SHIP Model Factors Cancer-relevant encodings and self-construal’s functional well-being Cancer-relevant beliefs and expectancies. Health self-efficacy. Cancer-relevant affects. Emotional well-being Negative emotion Cancer-relevant goals and values Need for information Cancer-relevant self-regulatory competencies and skills Participation in health care Health information competence Barriers to information Social support | The variables associated with the C-SHIP model appeared to have more frequent relationships with experiential as compared with didactic information seeking.
Nijland, 2008^5^ | Barrier type: user-level barriers; systems-level barriers. Barrier under study: application usability; incompatibility with current care. Target condition: various health complaints - symptom review | Qualitative | “caregiver” means physician in this article | Quality Demand Identified Patient Problems User-friendliness (n = 106, 40.8%) Navigation problems: Lack of a search engine Lack of an adequate search option Unclear navigation structure; hyperlinks were nonexistent or useless Unclear or unattractive layout of Web pages No features for printing information Technical problems: Software bugs Drop-down menus or back buttons failed Quality of care (relevance, comprehensibility of information; responsiveness) (n = 146, 56.1%) Problems with relevance of information: Information provided by the digital medical encyclopedia was too general to be useful Information provided by the virtual body was too limited to be useful Self-care advice insufficiently tailored to personal needs Problems with comprehensibility of information: Semantic mismatch between system and users because of unclear medical terms and lack of features to verbalize a problem in their own vocabulary Self-care advice hard to interpret Self-care advice frightening Problems with responsiveness: Caregiver used more than prescribed response time to answer patients ¡̄ questions Implementation (policy, training) (n = 8, 3.1%) Lack of education: Underuse or misuse of applications because of lack of education Uncertainty about regulations for using Internet for self-care
Morak, 2008^6^ | Barrier type: user-level barriers Barrier under study: application usability ; CHI application use too time consuming; Barrier under study: lack of technical infrastructure ; Patient preferences: opinion of using own mobile phone or PC Target condition: obesity | Non-validated survey | | About half of all participants were able to perform the data acquisition procedure after studying the manual without any additional explanation. In a few cases they obtained technical assistance from younger relatives. It was mainly patients with poor technical skills who contacted the helpdesk and requested further tuition by telephone
Steele, 2007^7^ | Barrier type: systems-level barriers. Barrier under study: application usability; knowledge literacy; lack of technical infrastructure. Target condition: physical activity/diet | Non-validated survey Qualitative | | Preference and satisfaction. Face to face=92% IM=69% IO=65% On a scale of 1–5 (strongly disagree to strongly agree) participants were also asked to rate their overall satisfaction related to understanding of the program content, and credibility of the information provided (Table 3). No significant differences in ratings across intervention groups were found. Participants reported similar means across groups for credibility [F(2, 154) = 1.36; p > 0.05] and understanding [F(2, 154) = 1.35; p > 0.05]. Responses to the ‘personal relevance and usefulness of the program activities’ in the FACE group were also high (4.3 0.69) (this item was assessed under website acceptability for the IM and IO groups). Seventy-four percent of IM, and 57% of the IO participants reported accessing the website from home. The rest of the IM participants accessed the Internet from work with a small percentage using Internet cafes and friends. The rest of the IO participants accessed the Internet outside of the home environment with the majority being at work, and a small percent at Internet cafes and university/cafe campuses. In terms of website usability, (user-friendliness, presentation, navigation, and relevance) participants rated the website favorably as shown in Table 4. There were no significant differences between IM and IO (p > 0.05).
Wangberg, 2008^8^ | Barrier type: User level Barrier under study: Patient preferences: perceived usefulness; lack of viral marketing; number of accesses. Target condition: diabetes | Non-validated survey, scale was not reported | Perceived usefulness might also be seen as a user lever barrier | The mean score on perceived usefulness was 3.6 (CI95% = 3.1–4.1), which corresponds to a slightly positive attitude. There was no difference in perceived usefulness between the two groups, F(1,27) = 0.29, P = .60 Four of 28 (14%) users would recommend the site to a friend. Use of the site was greatest during the first days, and declined rapidly thereafter. The mean time spent on the site was 45.2 min (CI95% = 37.1– 53.3), and the mean number of visits was 5.9 (CI95% = 3.9–8.0). The checkbox for the targeted daily self-care behavior was accessed most often, while only 4 of 28 users had downloaded any videos. There was no significant correlation between total time spent at the site and improvement in selfcare, r = .10, P = .60, nor between time spent at the site and perceived usefulness, r = .04, P = .83.
Lober, 2006^9^ | Barrier type: user-level barriers Barrier under study: knowledge literacy; physical limitations; cognitive impairment; health literacy; computer anxiety. Target condition: PHR use by elderly population. | Empirical based on trial data. Report by the nurse helping the patient to use the system. | | Elderly and disabled residents of the EHA were able to create and maintain a PHR, although the majority could not do so independently due to computer anxiety and a lack of computer literacy, cognitive and physical impairments, and health literacy
Stock, 2006^10^ | Barrier type: systems-level barriers. Barrier under study: application usability. Target condition: intellectual disabilities. | Empirical based on trial data | The average number of prompts for participant to complete the navigation using the pocket voyager interface was 1.41, while the average need for assistance when using the mainstream windows CE operating system was 5.34. Similarly participant made an average of only .78 errors when using the PVP. Compared to an average of 3.22 errors made when using the mainstream interface. One of the major barriers to access in the mainstream windows CE operating system is it complexity(several different methods for accomplishing the same task), button icons by themselves did not provide enough information to participants (non-readers) to enable independent program identification | see comments
Mangunkusumo, 2007^11^ | Barrier type: systems-level barriers Barrier under study: application usability. Patient preferences: acceptability; usability; credibility Target condition: physical activity/diet (specify) | Validated survey Non-validated survey | | Using the Internet for the adolescent preventive health care procedure is feasible and positively evaluated by users.
Ferney, 2006^12^ | Barrier type: systems-level barriers. Barrier under study: application usability. Patient preferences: no published studies on user-centered website design and development Target condition: physical activity website. | Qualitative | | Four major themes emerged, relating to ‘design’, ‘interactivity’, ‘environmental context’ and ‘content’. Recommendations for features and services recommended by participants under each of these themes are summarized in in the reported barriers column (question 3)
Temesgen, 2006^13^ | Barrier type: user-level barriers; systems-level barriers Barrier under study: application usability ; CHI application use too time consuming; incompatibility with current care; knowledge literacy; lack of technical infrastructure Patient preferences: goals and expectations; finances Target condition: HIV/AIDS | Non-validated survey | They gave patients laptops and internet access so did not assess the barrier. | our patient population was mainly rural-based adding geographic isolation and a relative lack of access to computers and the Internet to the many other difficulties commonly shared by HIV-infected people It was of interest to us to determine whether the ever-increasing complexities of HIV medicine and the transformation of HIV infection into a chronic Condition will be reflected in a greater utility and appreciation for systems like CHESS.
Owen, 2004^14^ | Barrier type: user-level barriers Barrier under study: application usability; lack of technical infrastructure. Patient preferences: expect internet based therapy to work. Target condition: breast cancer. | Non-validated survey( did examine internal consistency) | | An increasing percentage of women with breast cancer, nearly 70% in our most recent sample, have access to the internet, and nearly 66% report that internet-based APT is equally or more likely to result in improved physical and mental health than face-to-face therapy. When made aware of the availability of participating in internet-based APT, 45% asked to become a member of a small therapy group. Among patients who had access to the Internet and declined to participate, few cited logistical constraints as a reason for not being involved.
Lahdenpera, 2000^15^ | Barrier type: user-level barriers Barrier under study: confidentiality/privacy; incompatibility with current care; knowledge literacy; lack of technical infrastructure. Patient preferences: lack of personal contact with provider; patients attitude to IT Target condition: hypertension | Qualitative | | Even though the patients understood that the treatment of hypertension was up to them, they felt the need for something to remind them about the treatment. Their experience of IT and whether or not they had a computer at home did not influence the decision to participate in the intervention “If there is now is edoctorusing another computer at the health centre, there will be no benefit in using it. But when there is a doctor or a nurse, we get help from them, and then it is a good thing to use.”
Weber, 1998^16^ | Barrier type: user-level barriers Barrier under study: CHI application use too time consuming; knowledge literacy. Patient preferences: Target condition: mental health: psychiatric inpatients | Validated survey Non-validated survey | | Mixed results as far as the relationship between experience or attitude and opinion of the survey.
Jenkinson, 1998^17^ | Barrier type: user-level barriers Barrier under study: application usability Patient preferences: visual preferences and information needs of patients. Target condition: cancer: prostate | Qualitative | | Patients confirmed their need for more information about the diagnosis of prostate cancer, available treatments and side effects. Patients confirmed the computer as a suitable vehicle for conveying information. Visual preferences were noted about the interface/design/layout/type.
Paperny, 1997^18^ | Barrier type: user-level barriers Barrier under study: confidentiality/privacy; control of information; incompatibility with current care. Patient preferences: automated health education. Target condition: HIV/AIDS Other: STD | Qualitative | Interactive, computer-assisted identification of high-risk behaviors and health needs is thorough, accurate, painless, and easy and saves interviewer time. | Avoidance, mistrust, discomfort and breach of confidentiality in sharing sensitive problems is almost eliminated with this automated method of interview and health education
McTavish, 1994^19^ | Barrier type: user-level barriers Barrier under study: application usability ; knowledge literacy Target condition: breast cancer. | Empirical based on trial data Non-validated survey | The geographic barrier (location, cost, child care) were easily over some by their in-home use of the CHESS computer | CHESS appears to be extremely user-friendly and lack of computer experience is not a barrier to use.
Cavan, 2003^20^ | Barrier type: User barriers Barrier under study: application usability ; internet access Target condition: diabetes | Pilot study | Internet access is becoming more reliable, a rapid and preferably automated method of data entry would minimize the risk of data loss. | No data
Feil, 2000^21^ | Barrier type: user-level barriers Barrier under study: application usability; CHI application use too time consuming; knowledge literacy; lack of technical infrastructure; access. Target condition: diabetes | Non-validated survey | The home based intervention was free of charge, convenient (the participant were loaned a specialized computer) and designed to mitigate frequent participation barriers such as cost, transportation, child care, travel costs and work schedules | The result shows the internet intervention can appeal to a wide range of type 2 patients regardless of gender, disease severity and computer familiarity, thus mirroring the general public's adoption of the internet
Zeman, 2006^22^ | Barrier type: user-level barriers; systems-level barriers Barrier under study: application usability ; CHI application use: too time consuming; confidentiality/privacy; control of information ; cultural; Knowledge literacy; utility; Target condition: mental health : range of psychiatric conditions | Empirical based on trial data Non-validated survey; research assistant recorded this | Lack of physician interest and motivation is a critical barrier even if technology offers a low-cost alternative, requires few additional resources, is easy to use, and provides evidence-based diagnostic and treatment information. | Lack of physician interest and motivation is a critical barrier even if technology offers a low-cost alternative, requires few additional resources, is easy to use, and provides evidence-based diagnostic and treatment information.
Bryce, 2008^23^ | Barrier type: user-level barriers, systems-level barriers. Barrier under study: Comparison of preportal participants to portal users about interest in a number of features of a portal. Also, participants were queried about the acceptability of fees. The substantial investment to develop a portal was discussed as a system level barrier. Target condition: diabetes | Qualitative | In general, preportal participants anticipated features to be more useful than portal users actually found them to be, with the exception of electronic communication with healthcare practices. Most participants did not find fees acceptable. | Potential and actual users of a diabetes portal favored capabilities aimed largely at self management, education, and communication, but ratings of actual users were not better than those of potential users. Most participants were opposed to paying for access.
Leslie, 2005^24^ | Barrier type: User-level barriers Barrier under study: application usability Target condition: Physical Activity/ Diet/ Obesity | Non-validated survey | | The use of websites to deliver health behavior change programs provides many new opportunities and challenges Websites may be a far more ‘passive’ medium than has been previously assumed. It may be necessary to make websites more dynamic and to update website material regularly to make them more appealing and useful to potential users. The key challenge in providing effective programs is in finding the most appropriate methods to recruit, actively engage and maintain participant interest in the program materials.
Ferrer-Roca, 2004^25^ | Barrier type: User-level barriers, systems-level barriers. Barrier under study: application usability, User satisfaction Target condition: Diabetes | Non-validated survey | | the trial results suggest that SMS may provide a simple, fast, efficient and low-cost adjunct to the medical management of diabetes at a distance. In our case it was particularly useful for elderly persons and teenagers, age groups that are known to have difficulty in controlling their diabetes well.
Lenert, 2003^26^ | Barrier type: User-level barriers Barrier under study: application usability, complex design Target condition: Smoking Cessation | Non-validated survey | | this pilot study suggests that design of Internet applications that motivate changes in health behavior may need to differ from applications designed to educate and inform.
Kressig, 2002^27^ | Barrier type: user-level barriers Barrier under study: application usability, user friendliness Target condition: Physical Activity/ Diet/ Obesity | Non-validated survey | | the data from this study support the potential of interactive technology in health promotion among the expanding older population
Brug, 1998^28^ | Barrier type: user-level barriers Barrier under study: application usability Target condition: Physical Activity/ Diet/ Obesity | Non-validated survey | | computer-generated individualized feedback can be effective in inducing recommended dietary changes and that iterative feedback can increase the longer term impact of computertailored nutrition education on fat reduction.
Boberg, 1995^29^ | Barrier type: user-level barriers Barrier under study: application usability Target condition: HIV/AIDS | Non-validated survey | | This study demonstrates that computers, which are often characterized as sterile, information-only, and intimidating, can be used very successfully to provide information, analysis, and support to people facing a health crisis such as HIV infection
Shaw, 2001^30^ | Barrier type: System-level barriers Barrier under study: application usability Target condition: all cancer | Non-validated survey | | The results of this study demonstrate that the addition of a multimedia interactive program to the process of patient education may affect patient satisfaction and the delivery of information required for informed consent
Strecher, 1994^31^ | Barrier type: User-level barriers Barrier under study: application usability Target condition: Smoking Cessation | Non-validated survey | | Results from both studies indicate positive effects of computer-tailored smoking messages among moderate to light smokers

Reference List

1 Simon C, Acheson L, Burant C et al. Patient interest in recording family histories of cancer via the Internet. Genet Med 2008; 10(12):895–902.

2 Cimino JJ, Patel VL, Kushniruk AW. What do patients do with access to their medical records? Stud Health Technol Inform 2001; 84(Pt 2):1440–4.

3 Keselman A, Slaughter L, Smith CA et al. Towards consumer-friendly PHRs: patients' experience with reviewing their health records. AMIA Annu Symp Proc 2007; 399–403.

4 Shaw BR, Dubenske LL, Han JY et al. Antecedent characteristics of online cancer information seeking among rural breast cancer patients: an application of the Cognitive-Social Health Information Processing (C-SHIP) model. J Health Commun 2008; 13(4):389–408.

5 Nijland N, van Gemert-Pijnen J, Boer H, Steehouder MF, Seydel ER. Evaluation of internet-based technology for supporting self-care: problems encountered by patients and caregivers when using self-care applications. J Med Internet Res 2008; 10(2):e13.

6 Morak J, Schindler K, Goerzer E et al. A pilot study of mobile phone-based therapy for obese patients. J Telemed Telecare 2008; 14(3):147–9.

7 Steele R, Mummery KW, Dwyer T. Development and process evaluation of an internet-based physical activity behaviour change program. Patient Educ Couns 2007; 67(1–2):127–36.

8 Wangberg SC. An Internet-based diabetes self-care intervention tailored to self-efficacy. Health Educ Res 2008; 23(1):170–9.

9 Lober WB, Zierler B, Herbaugh A et al. Barriers to the use of a personal health record by an elderly population. AMIA Annu Symp Proc 2006; 514–8.

10 Stock SE, Davies DK, Davies KR, Wehmeyer ML. Evaluation of an application for making palmtop computers accessible to individuals with intellectual disabilities. J Intellect Dev Disabil 2006; 31(1):39–46.

11 Mangunkusumo R, Brug J, Duisterhout J, de Koning H, Raat H. Feasibility, acceptability, and quality of Internet-administered adolescent health promotion in a preventive-care setting. Health Educ Res 2007; 22(1):1–13.

12 Ferney SL, Marshall AL. Website physical activity interventions: preferences of potential users. Health Educ Res 2006; 21(4):560–6.

13 Temesgen Z, Knappe-Langworthy JE, St Marie MM, Smith BA, Dierkhising RA. Comprehensive Health Enhancement Support System (CHESS) for people with HIV infection. AIDS Behav 2006; 10(1):35–40.

14 Owen JE, Klapow JC, Roth DL, Nabell L, Tucker DC. Improving the effectiveness of adjuvant psychological treatment for women with breast cancer: the feasibility of providing online support. Psychooncology 2004; 13(4):281–92.

15 Lahdenpera TS, Kyngas HA. Patients' views about information technology in the treatment of hypertension. J Telemed Telecare 2000; 6(2):108–13.

16 Weber B, Fritze J, Schneider B, Simminger D, Maurer K. Computerized self-assessment in psychiatric in-patients: acceptability, feasibility and influence of computer attitude. Acta Psychiatr Scand 1998; 98(2):140–5.

17 Jenkinson J, Wilson-Pauwels L, Jewett MA, Woolridge N. Development of a hypermedia program designed to assist patients with localized prostate cancer in making treatment decisions. J Biocommun 1998; 25(2):2–11.

18 Paperny DM. Computerized health assessment and education for adolescent HIV and STD prevention in health care settings and schools. Health Educ Behav 1997; 24(1):54–70.

19 McTavish FM, Gustafson DH, Owens BH et al. CHESS: An interactive computer system for women with breast cancer piloted with an under-served population. Proc Annu Symp Comput Appl Med Care 1994; 599–603.

20 Cavan DA, Everett J, Plougmann S, Hejlesen OK. Use of the Internet to optimize self-management of type 1 diabetes: preliminary experience with DiasNet. 2003; 9 Suppl 1.

21 Feil EG, Glasgow RE, Boles S, McKay HG. Who participates in internet-based self-management programs? A study among novice computer users in a primary care setting. 2000; 26(5):806–11.

22 Zeman L, Johnson D, Arfken C, Smith T, Opoku P. Lessons learned: challenges implementing a personal digital assistant (PDA) to assess behavioral health in primary care. Families, Systems & Health: The Journal of Collaborative Family HealthCare 2006; 24(3):286–98.

23 Bryce CL, Zickmund S, Hess R et al. Value versus user fees: perspectives of patients before and after using a web-based portal for management of diabetes. Telemed J E Health 2008; 14(10):1035–43.

24 Leslie E, Marshall AL, Owen N, Bauman A. Engagement and retention of participants in a physical activity website. 2005; 40(1):54–9.

25 Ferrer-Roca O, C+írdenas A, Diaz-Cardama A, Pulido P. Mobile phone text messaging in the management of diabetes. 2004; 10(5):282–5.

26 Lenert L, Mu+_oz RF, Stoddard J et al. Design and pilot evaluation of an internet smoking cessation program. 2003; 10(1):16–20.

27 Kressig RW, Echt KV. Exercise prescribing: Computer application in older adults. 2002; 42(2):273–7.

28 Brug J, Glanz K, Van Assema P, Kok G, Van Breukelen GJP. The Impact of Computer-Tailored Feedback and Iterative Feedback on Fat, Fruit, and Vegetable Intake. 1998; 25(4):517–31.

29 Boberg EW, Gustafson DH, Hawkins RP et al. Development, acceptance, and use patterns of a computer-based education and social support system for people living with AIDS/HIV infection. 1995; 11(2):289–311.

30 Shaw MJ, Beebe TJ, Tomshine PA, Adlis SA, Cass OW. A randomized, controlled trial of interactive, multimedia software for patient colonoscopy education. 2001; 32(2):142–7.

31 Strecher VJ, Kreuter M, Den Boer D-J, Kobrin S, Hospers HJ, Skinner CS. The effects of computer-tailored smoking cessation messages in family practice settings. 1994; 39(3):262–70.