# Appendix F List of Excluded Articles

A new strategy to empower people in Africa. World Health 97;(6):4–5

No health informatics application

Adler K G. Web portals in primary care: an evaluation of patient readiness and willingness to pay for online services. J Med Internet Res 2006;8(4):e26

No health informatics application;

Health informatics application is for general information only AND is not tailored to the individual consumer

Ahmad F, Hogg-Johnson S, Skinner H A. Assessing patient attitudes to computerized screening in primary care: psychometric properties of the computerized lifestyle assessment scale. J Med Internet Res 2008;10(2):e11

Study of a point of care device

Allenby A, Matthews J, Beresford J et al. The application of computer touch-screen technology in screening for psychosocial distress in an ambulatory oncology setting. Eur J Cancer Care (Engl) 2002;11(4):245–53

No health informatics application;

Study of a point of care device

An J. Correlates and predictors of consumers’ health information and services usage behavior on the Internet: A structural equation modeling approach. New York University, 2005. (Doctoral dissertation)

No original data;

Other*

An L C, Schillo B A, Saul J E et al. Utilization of smoking cessation informational, interactive, and online community resources as predictors of abstinence: cohort study. J Med Internet Res 2008;10(5):e55

Not a RCT and not a study addressing barriers

Anderson PF, Wilson B. Rapid development of a craniofacial consumer health Web site: part one, what happens before content and coding.. Journal of Consumer Health on the Internet 2007;11(2):13–31

Health informatics application is for general information only AND is not tailored to the individual consumer;

No original data

Andersson G, Bergstrom J, Hollandare F et al. Internet-based self-help for depression: randomised controlled trial. Br J Psychiatry 2005;187456–61

Study of a point of care device

Andersson G, Lundstrom P, Strom L. Internet-based treatment of headache: does telephone contact add anything?. Headache 2003;43(4):353–61

Study of a point of care device

Anhoj J, Nielsen L. Quantitative and qualitative usage data of an Internet-based asthma monitoring tool. J Med Internet Res 2004;6(3):e23

Study of a point of care device

Apkon M, Mattera J A, Lin Z et al. A randomized outpatient trial of a decision-support information technology tool. Arch Intern Med 2005;165(20):2388–94

Study of a point of care device

Balmford J, Borland R, Benda P. Patterns of use of an automated interactive personalized coaching program for smoking cessation. J Med Internet Res 2008;10(5):e54

Not a RCT, and not a study addressing barriers;

Other*

Bandy M. Health information for patients and consumers.: Health information for patients and consumers.. 2000;325–350

No health informatics application;

Health informatics application does not apply to the consumer;

Health informatics application is for general information only AND is not tailored to the individual consumer

Barnason S, Zimmerman L, Nieveen J et al. Impact of a home communication intervention for coronary artery bypass graft patients with ischemic heart failure on self-efficacy, coronary disease risk factor modification, and functioning. Heart Lung 2003;32(3):147–58

No health informatics application;

Study of a point of care device

Barrera M, Glasgow R E, McKay H G et al. Do Internet-based support interventions change perceptions of social support?: An experimental trial of approaches for supporting diabetes self-management. Am J Community Psychol 2002;30(5):637–54

Health informatics application is for general information only AND is not tailored to the individual consumer;

Study of a point of care device

Barry K L, Fleming M F. Computerized administration of alcoholism screening tests in a primary care setting. J Am Board Fam Pract 90;3(2):93–8

Other*

Bechtel-Blackwell D A. Computer-assisted self-interview and nutrition education in pregnant teens. Clin Nurs Res 2002;11(4):450–62

Health informatics application is for general information only AND is not tailored to the individual consumer

Berman R L, Iris M A, Bode R et al. The effectiveness of an online mind-body intervention for older adults with chronic pain. J Pain 2009;10(1):68–79

Other*

Bernhardt J M, Lariscy R A W, Parrott R L et al. Perceived barriers to internet-based health communication on human genetics. 2002;7(4):325–340

Other*

Bexelius C, Honeth L, Ekman A et al. Evaluation of an internet-based hearing test--comparison with established methods for detection of hearing loss. J Med Internet Res 2008;10(4):e32

Not a RCT, and not a study addressing barriers;

Other*

Birru M S, Monaco V M, Charles L et al. Internet usage by low-literacy adults seeking health information: an observational analysis. J Med Internet Res 2004;6(3):e25

Health informatics application is for general information only AND is not tailored to the individual consumer

Blas M M, Alva I E, Cabello R et al. Internet as a tool to access high-risk men who have sex with men from a resource-constrained setting: a study from Peru. Sex Transm Infect 2007;83(7):567–70

No health informatics application

Health informatics application does not apply to the consumer

Block G, Sternfeld B, Block C H et al. Development of Alive! (A Lifestyle Intervention Via Email), and its effect on health-related quality of life, presenteeism, and other behavioral outcomes: randomized controlled trial. J Med Internet Res 2008;10(4):e43

Other*

Bonniface L, Green L. Finding a new kind of knowledge on the HeartNET website. Health Information & Libraries Journal 2007-; 2467–76

Health informatics application is for general information only AND is not tailored to the individual consumer;

Not a RCT, and not a study addressing barriers

Borbolla D, Giunta D, Figar S et al. Effectiveness of a chronic disease surveillance systems for blood pressure monitoring. Stud Health Technol Inform 2007;129(Pt 1):223–7

No health informatics application

Health informatics application does not apply to the consumer

Borckardt J J, Younger J, Winkel J et al. The computer-assisted cognitive/imagery system for use in the management of pain. Pain Res Manag 2004;9(3):157–62

Health informatics application does not apply to the consumer

Borland R, Balmford J, Hunt D. The effectiveness of personally tailored computer-generated advice letters for smoking cessation. Addiction 2004;99(3):369–77

No health informatics application

Borland R, Balmford J, Segan C et al. The effectiveness of personalized smoking cessation strategies for callers to a Quitline service. Addiction 2003;98(6):837–46

No health informatics application

Study of a point of care device

Borzekowski D L, Rickert V I, VI. Urban girls, internet use, and accessing health information. J Pediatr Adolesc Gynecol 2000;13(2):94–5

No health informatics application;

Other*

Bosworth K, Gustafson D H. CHESS: Providing Decision Support for Reducing Health Risk Behavior and Improving Access to Health Services. 91;21(3):93–104

Not a RCT, and not a study addressing barriers;

Other*

Bouhaddou O, Lambert J G, Miller S. Consumer health informatics: knowledge engineering and evaluation studies of medical HouseCall. Proc AMIA Symp 98;612–6

Not a RCT, and not a study addressing barriers;

Other*

Boukhors Y, Rabasa-Lhoret R, Langelier H et al. The use of information technology for the management of intensive insulin therapy in type 1 diabetes mellitus. Diabetes Metab 2003;29(6):619–27

No health informatics application

Braithwaite S R, Fincham F D. A randomized clinical trial of a computer based preventive intervention: replication and extension of ePREP. J Fam Psychol 2009;23(1):32–8

Other*

Brennan P F. Health informatics and community health: support for patients as collaborators in care. Methods Inf Med 99;38(4–5):274–8

No original data

Brug J. Dutch research into the development and impact of computer-tailored nutrition education. European Journal of Clinical Nutrition 1999;53(SUPPL. 2): S78–82

No original data

Bukachi F, Pakenham-Walsh N. Information technology for health in developing countries. Chest 2007;132(5):1624–30

No health informatics application;

Study of a point of care device

Bull S S, Phibbs S, Watson S et al. What do young adults expect when they go online? Lessons for development of an STD/HIV and pregnancy prevention website. J Med Syst 2007;31(2):149–58

Health informatics application is for general information only AND is not tailored to the individual consumer

Campbell M K, DeVellis B M, Strecher V J et al. Improving dietary behavior: The effectiveness of tailored messages in primary care settings. American Journal of Public Health 1994; 84(5):783–787

No health informatics application

Campbell M K, Tessaro I, DeVellis B et al. Effects of a tailored health promotion program for female blue-collar workers: Health works for women. Preventive Medicine 2002;34(3):313–323

Other*

Campbell R. Older women and the internet. J Women Aging 2004;16(1–2):161–74

No health informatics application

Campbell RJ, Wabby J. The elderly and the Internet: a case study.. Internet Journal of Health 2003;3(1):11p

Not a RCT, and not a study addressing barriers

Campbell SE. Individualised computer generated nutrition information plus interative feedback reduced dietary fat and increased fruit and vegetable intake [commentary on Brug J, Glanz K, Van Assema P, et al. The impact of computer-tailored feedback and iterative feedback on fat, fruit, and vegetable intake. HEALTH EDUC BEHAV 1998 Aug;25:517–31].. Evidence-Based Nursing 99;2(3):83

No original data

Carlbring P, Smit F. Randomized trial of internet-delivered self-help with telephone support for pathological gamblers. J Consult Clin Psychol 2008;76(6):1090–4

Other*

Carlfjord S, Nilsen P, Leijon M et al. Computerized lifestyle intervention in routine primary health care: evaluation of usage on provider and responder levels. Patient Educ Couns 2009;75(2):238–43

Other*

Casper G R, Brennan P F, Burke L J et al. HeartCareII: Patients’ Use of a Home Care Web Resource. Stud Health Technol Inform 2009;146139–43

Other*

Chan D S, Callahan C W, Hatch-Pigott V B et al. Internet-based home monitoring and education of children with asthma is comparable to ideal office-based care: results of a 1-year asthma in-home monitoring trial. Pediatrics 2007;119(3):569–78

Study of a point of care device

Chandra A, Rutsohn P, Carlisle MB. Utilization of the Internet by rural West Virginia consumers.. Journal of Consumer Health on the Internet 2004;8(2):45–59

Health informatics application does not apply to the consumer;

Health informatics application is for general information only AND is not tailored to the individual consumer

Chiang M F, Starren J. Evaluation of consumer health website accessibility by users with sensory and physical disabilities. Stud Health Technol Inform 2004;107(Pt 2):1128–32

Health informatics application is for general information only AND is not tailored to the individual consumer

Chinman M, Young A S, Schell T et al. Computer-assisted self-assessment in persons with severe mental illness. J Clin Psychiatry 2004;65(10):1343–51

No health informatics application;

Health informatics application is for general information only AND is not tailored to the individual consumer

Cho J H, Lee H C, Lim D J et al. Mobile communication using a mobile phone with a glucometer for glucose control in Type 2 patients with diabetes: as effective as an Internet-based glucose monitoring system. J Telemed Telecare 2009;15(2):77–82

No health informatics application;

Study of a point of care device

Christensen H, Griffiths K, Groves C et al. Free range users and one hit wonders: Community users of an internet-based cognitive behaviour therapy program. Australian and New Zealand Journal of Psychiatry 2006;40(1):59–62

Not a RCT, and not a study addressing barriers

Cintron A, Phillips R, Hamel M B. The effect of a web-based, patient-directed intervention on knowledge, discussion, and completion of a health care proxy. J Palliat Med 2006;9(6):1320–8

Health informatics application is for general information only AND is not tailored to the individual consumer

Civan A, Skeels M M, Stolyar A et al. Personal health information management: consumers’ perspectives. AMIA Annu Symp Proc 2006;156–60

Other*

Clarke G, Eubanks D, Reid E et al. Overcoming Depression on the Internet (ODIN) (2): a randomized trial of a self-help depression skills program with reminders. J Med Internet Res 2005;7(2):e16

Study of a point of care device

Clayton A E, McNutt L A, Homestead H L et al. Public health in managed care: a randomized controlled trial of the effectiveness of postcard reminders. Am J Public Health 99;89(8):1235–7

No health informatics application

Cobb N K, Graham A L, Bock B C et al. Initial evaluation of a real-world internet smoking cessation system. Nicotine Tob Res. 2005;7(2):207–216

Not a RCT, and not a study addressing barriers

Coile R C. E-health: Reinventing healthcare in the information age. Journal of Healthcare Management. 2000;45(3):206–210

No health informatics application

Col N F, Ngo L, Fortin J M et al. Can computerized decision support help patients make complex treatment decisions? A randomized controlled trial of an individualized menopause decision aid. Med Decis Making 2007;27(5):585–98

No health informatics application;

Health informatics application does not apply to the consumer

Cook R F, Billings D W, Hersch R K et al. A field test of a web-based workplace health promotion program to improve dietary practices, reduce stress, and increase physical activity: Randomized controlled trial. Journal of Medical Internet Research 2007;9:e17

Other*

Cox A, Boehm M, Summers R et al. Patient perspective. Using a virtual community to support healthcare. Quality in Primary Care 2003;11(2):143–145

Health informatics application is for general information only AND is not tailored to the individual consumer;

No original data

Cummings E, Turner P. Patient self-management and chronic illness: evaluating outcomes and impacts of information technology. Stud Health Technol Inform 2009;143229–34

No health informatics application;

Study of a point of care device

Cummings E, Turner P. Patient self-management and chronic illness: evaluating outcomes and impacts of information technology. Stud Health Technol Inform 2009;143229–34

Other*

Cunningham J A, Humphreys K, Koski-Jannes A. Providing personalized assessment feedback for problem drinking on the internet: A pilot project. 2000;61(6):794–798

Not a RCT and not a study addressing barriers;

Other*

Cunningham J A, Selby P, van Mierlo T. Integrated online services for smokers and drinkers? Use of the check your drinking assessment screener by participants of the Stop Smoking Center. Nicotine Tob Res 2006;8 Suppl 1S21–5

No health informatics application;

Study of a point of care device

Curioso W H, Kurth A E. Access, use and perceptions regarding Internet, cell phones and PDAs as a means for health promotion for people living with HIV in Peru. BMC Med Inform Decis Mak 2007;724

Health informatics application is for general information only AND is not tailored to the individual consumer

Curioso W H, Kurth A E. Access, use and perceptions regarding Internet, cell phones and PDAs as a means for health promotion for people living with HIV in Peru. BMC Med Inform Decis Mak 2007;724

Other*

Damster G, Williams J R. The Internet, virtual communities and threats to confidentiality. S Afr Med J 99;89(11):1175–8

Health informatics application is for general information only AND is not tailored to the individual consumer;

No original data

Danaher B G, Boles S M, Akers L et al. Defining participant exposure measures in Web-based health behavior change programs. J Med Internet Res 2006;8(3):e15

No health informatics application;

Other*

Dart J, Gallois C, Yellowlees P. Community health information sources--a survey in three disparate communities. Aust Health Rev 2008;32(1):186–96

Health informatics application is for general information only AND is not tailored to the individual consumer

Dart J. The internet as a source of health information in three disparate communities. Aust Health Rev 2008;32(3):559–69

Health informatics application is for general information only AND is not tailored to the individual consumer

Davison B J, Degner L F. Feasibility of using a computer-assisted intervention to enhance the way women with breast cancer communicate with their physicians. Cancer Nurs 2002;25(6):417–24

Other*

Dawson A J, Konkin D, Riordan D et al. Education about genetic testing for breast cancer susceptibility: Patient preferences for a computer program or genetic counselor. American Journal of Medical Genetics 2001;103(1):24–31

Health informatics application is for general information only AND is not tailored to the individual consumer;

Not a RCT, and not a study addressing barriers

De Bourdeaudhuij I, Stevens V, Vandelanotte C et al. Evaluation of an interactive computer-tailored nutrition intervention in a real-life setting. Annals of Behavioral Medicine 2007;33(1):39–48

Other*

Demiris G, Finkelstein S M, Speedie S M. Considerations for the design of a Web-based clinical monitoring and educational system for elderly patients. Journal of the American Medical Informatics Association 2001;8(5):468–472

No original data

Demiris G, Rantz M, Aud M et al. Older adults’ attitudes towards and perceptions of “smart home” technologies: a pilot study. Med Inform Internet Med 2004;29(2):87–94

No health informatics application;

Health informatics application does not apply to the consumer

Detailed report on physician and patient use of the Web. Internet Healthc Strateg 2003;5(5):5–6

Health informatics application is for general information only AND is not tailored to the individual consumer;

No original data

Dilts D, Ridner S H, Franco A et al. Patients with cancer and e-mail: implications for clinical communication. Support Care Cancer 2008;

Health informatics application is for general information only AND is not tailored to the individual consumer

Dimeff L A, McNeely M. Computer-enhanced primary care practitioner advice for high-risk college drinkers in a student primary health-care setting. Cognitive and Behavioral Practice 2000;7(1):82–100

Not a RCT, and not a study addressing barriers;

Other*

Dini E F, Linkins R W, Sigafoos J. The impact of computer-generated messages on childhood immunization coverage. Am J Prev Med 2000;18(2):132–9

Health informatics application does not apply to the consumer;

Study of a point of care device

Dolezal-Wood S, Belar C D, Snibbe J. A Comparison of Computer-Assisted Psychotherapy and Cognitive-Behavioral Therapy in Groups. Journal of Clinical Psychology in Medical Settings 98;5(1):103–115

Other*

Doumas D M, McKinley L L, Book P. Evaluation of two Web-based alcohol interventions for mandated college students. J Subst Abuse Treat 2009;36(1):65–74

Other*

Draper S, Coffman S. Logging on: what it takes to provide patients with computer access. Biomed Instrum Technol 2004–2005;Suppl17–9

No original data

Dreault RT. Information anxiety. Mississippi RN 2000;62(3):11–14

No health informatics application

Edwards A, Thomas R, Williams R et al. Presenting risk information to people with diabetes: evaluating effects and preferences for different formats by a web-based randomised controlled trial. Patient Educ Couns 2006;63(3):336–49

Health informatics application is for general information only AND is not tailored to the individual consumer

Ellison G L, Weinrich S P, Lou M et al. A randomized trial comparing web-based decision aids on prostate cancer knowledge for African-American men. J Natl Med Assoc 2008;100(10):1139–45

Not a RCT, and not a study addressing barriers

Emmons K M, Wong M, Puleo E et al. Tailored computer-based cancer risk communication: Correcting colorectal cancer risk perception. Journal of Health Communication 2004;9(2):127–141

Other*

Enterprise scheduling may improve patient access. ‘‘Transparent’’ registration is the goal. Patient Focus Care Satisf 98;6(7):83–6

No health informatics application;

Health informatics application is for general information only AND is not tailored to the individual consumer

Ervin N E, Berry M M. Community readiness for a computer-based health information network. J N Y State Nurses Assoc 2006;37(1):5–11

No health informatics application

Escoffery C, McCormick L, Bateman K. Development and process evaluation of a web-based smoking cessation program for college smokers: innovative tool for education. Patient Educ Couns 2004;53(2):217–25

Other*

Etter J F, Perneger T V. Post-intervention effect of a computer tailored smoking cessation programme. J Epidemiol Community Health 2004;58(10):849–51

No health informatics application;

Other*

Eysenbach G. From intermediation to disintermediation and apomediation: new models for consumers to access and assess the credibility of health information in the age of Web2.0. Stud Health Technol Inform 2007;129(Pt 1):162–6

No health informatics application;

Study of a point of care device

Feldstein A C, Smith D H, Perrin N et al. Improved therapeutic monitoring with several interventions: a randomized trial. Arch Intern Med 2006;166(17):1848–54

No health informatics application

Ferrer-Roca O, C+írdenas A, Diaz-Cardama A et al. Mobile phone text messaging in the management of diabetes. Journal of Telemedicine and Telecare 2004;10(5):282–285

Other*

Ferriman A. Patients get access to evidence based, online health information. BMJ 2002;325(7365):618

No original data

Finfgeld-Connett D, Madsen R. Web-based treatment of alcohol problems among rural women. J Psychosoc Nurs Ment Health Serv 2008;46(9):46–53

Health informatics application does not apply to the consumer;

Other*

Fitzgibbon M L, Stolley M R, Schiffer L et al. Two-year follow-up results for Hip-Hop to Health Jr.: A randomized controlled trial for overweight prevention in preschool minority children. Journal of Pediatrics 2005;146(5):618–625

No health informatics application

Ford P. Brief report. Is the Internet changing the relationship between consumers and practitioners? Journal for Healthcare Quality: Promoting Excellence in Healthcare 2000;22(5):41–43

No health informatics application;

Health informatics application is for general information only AND is not tailored to the individual consumer

Franklin V L, Greene A, Waller A et al. Patients’ engagement with “Sweet Talk” - a text messaging support system for young people with diabetes. J Med Internet Res 2008;10(2):e20

No health informatics application;

Other*

Friedman D B, Kao E K. A comprehensive assessment of the difficulty level and cultural sensitivity of online cancer prevention resources for older minority men. Prev Chronic Dis 2008;5(1):A07

No health informatics application;

Health informatics application is for general information only AND is not tailored to the individual consumer

Fung V, Ortiz E, Huang J et al. Early experiences with e-health services (1999–2002): promise, reality, and implications. Med Care 2006;44(5):491–6

Study of a point of care device

Garth McKay H, Glasgow R E, Feil E G et al. Internet-based diabetes self-management and support: Initial outcomes from the diabetes network project. Rehabilitation Psychology 2002;47(1):31–48

No health informatics application;

Health informatics application does not apply to the consumer

Gerressu M, French R S. Using the Internet to promote sexual health awareness among young people. J Fam Plann Reprod Health Care 2005;31(4):267, 269–70

No original data

Glasgow R E, Barrera M, Mckay H G et al. Social support, self-management, and quality of life among participants in an Internet-based diabetes support program: A multi-dimensional investigation. Cyberpsychology and Behavior 99;2(4):271–281

Not a RCT, and not a study addressing barriers;

Other*

Goulis D G, Giaglis G D, Boren S A et al. Effectiveness of home-centered care through telemedicine applications for overweight and obese patients: a randomized controlled trial. Int J Obes Relat Metab Disord 2004;28(11):1391–8

Study of a point of care device;

Other*

Graham A L, Bock B C, Cobb N K et al. Characteristics of smokers reached and recruited to an internet smoking cessation trial: a case of denominators. Nicotine Tob Res 2006;8 Suppl 1S43–8

No health informatics application;

Health informatics application does not apply to the consumer

Graham W, Smith P, Kamal A et al. Randomised controlled trial comparing effectiveness of touch screen system with leaflet for providing women with information on prenatal tests. BMJ 2000;320(7228):155–160

No health informatics application;

Health informatics application is for general information only AND is not tailored to the individual consumer

Gruber K, Moran P J, Roth W T et al. Computer-Assisted Cognitive Behavioral Group Therapy for Social Phobia. Behavior Therapy 2001;32(1):155–165

Study of a point of care device;

Not a RCT, and not a study addressing barriers

Gustafson D H, Bosworth K, Chewning B et al. Computer-based health promotion: combining technological advances with problem-solving techniques to effect successful health behavior changes. Annual Review of Public health 87 ;(8)387–415

No original data

Gustafson D H, Hawkins R P, Boberg E W et al. CHESS: ten years of research and development in consumer health informatics for broad populations, including the underserved. Stud Health Technol Inform 2001;84(Pt 2):1459–563

No original data

Gustafson D H, McTavish F M, Boberg E et al. Empowering patients using computer based health support systems. Quality in Health Care 99;8(1):49–56

No original data

Gustafson D H, McTavish F M, Stengle W et al. Reducing the digital divide for low-income women with breast cancer: a feasibility study of a population-based intervention. J Health Commun 2005;10 Suppl 1173–93

Study of a point of care device

Gustafson D H, McTavish F M, Stengle W et al. Use and Impact of eHealth System by Low-income Women With Breast Cancer. J Health Commun 2005;10 Suppl 1195–218

Not a RCT, and not a study addressing barriers

Gustafson D H, Robinson T N, Ansley D et al. Consumers and evaluation of interactive health communication applications. American Journal of Preventive Medicine 99;16(1):23–29

Health informatics application is for general information only AND is not tailored to the individual consumer;

No original data

Gutteling J J, Busschbach J J, de Man R A et al. Logistic feasibility of health related quality of life measurement in clinical practice: results of a prospective study in a large population of chronic liver patients. Health Qual Life Outcomes 2008;6(1):97

Health informatics application does not apply to the consumer

Haerens L, Deforche B, Maes L et al. Evaluation of a 2-year physical activity and healthy eating intervention in middle school children. Health Education Research 2006;21(6):911–921

No health informatics application

Hanauer D, Dibble E, Fortin J et al. Internet use among community college students: implications in designing healthcare interventions. J Am Coll Health 2004;52(5):197–202

No health informatics application;

Health informatics application is for general information only AND is not tailored to the individual consumer

Hartmann C W, Sciamanna C N, Blanch D C et al. A website to improve asthma care by suggesting patient questions for physicians: qualitative analysis of user experiences. J Med Internet Res 2007;9(1):e3

Other*

Harvey K, Churchill D, Crawford P et al. Health communication and adolescents: what do their emails tell us?. Fam Pract 2008;25(4):304–11

No health informatics application

Harvey-Berino J, Pintauro S, Buzzell P et al. Does using the Internet facilitate the maintenance of weight loss? International Journal of Obesity 2002;26(9):1254–1260

Not a RCT and not a study addressing barriers;

Other*

Harvey-Berino J, Pintauro S, Buzzell P et al. Effect of internet support on the long-term maintenance of weight loss. Obes Res 2004;12(2):320–9

Health informatics application is for general information only AND is not tailored to the individual consumer;

Study of a point of care device

Hayashi A, Kayama M, Ando K et al. Analysis of subjective evaluations of the functions of tele-coaching intervention in patients with spinocerebellar degeneration. NeuroRehabilitation 2008;23(2):159–69

Health informatics application does not apply to the consumer;

Study of a point of care device

Heidenreich P A, Chacko M, Goldstein M K et al. ACE inhibitor reminders attached to echocardiography reports of patients with reduced left ventricular ejection fraction. Am J Med 2005;118(9):1034–7

No health informatics application

Hibbard J H, Peters E, Dixon A et al. Consumer competencies and the use of comparative quality information: it isn’t just about literacy. Med Care Res Rev 2007;64(4):379–94

No health informatics application;

Health informatics application does not apply to the consumer

Hill W, Weinert C, Cudney S. Influence of a computer intervention on the psychological status of chronically ill rural women: preliminary results. Nurs Res 2006;55(1):34–42

Health informatics application is for general information only AND is not tailored to the individual consumer;

Study of a point of care device

Holmes-Rovner M, Stableford S, Fagerlin A et al. Evidence-based patient choice: a prostate cancer decision aid in plain language. BMC Med Inform Decis Mak 2005;516

No health informatics application

Hopper K D, Zajdel M, Hulse S F et al. Interactive method of informing patients of the risks of intravenous contrast media. Radiology 94;192(1):67–71

Health informatics application does not apply to the consumer;

Other*

Huber J T, Huggins D W. Assessing electronic information access and use in long-term care facilities in north Texas. Bull Med Libr Assoc 2000;88(2):187–9

Health informatics application does not apply to the consumer

Hughes S, Dennison C R. Progress in prevention: how can we help patients seek information on the World Wide Web?: an opportunity to improve the “net effect”. J Cardiovasc Nurs 2008;23(4):324–5

Health informatics application is for general information only AND is not tailored to the individual consumer;

No original data

Hung S H, Hwang S L, Su M J et al. An evaluation of a weight-loss program incorporating E-learning for obese junior high school students. Telemed J E Health 2008;14(8):783–92

Not a RCT, and not a study addressing barriers

Huss K, Salerno M, Huss R W. Computer-assisted reinforcement of instruction: effects on adherence in adult atopic asthmatics. Research in nursing & health 91;14(4):259–267

Health informatics application is for general information only AND is not tailored to the individual consumer

Irvine A B, Ary D V, Grove D A et al. The effectiveness of an interactive multimedia program to influence eating habits. Health Education Research 2004;19(3):290–305

No health informatics application

Izenberg N, Lieberman D A. The Web, communication trends, and children’s health. Part 3: The Web and health consumers. Clin Pediatr (Phila) 98;37(5):275–85

No original data

Jackson S J. Access to medical information: essential for better patient care. J Tenn Med Assoc 72;65(10):902–6

Health informatics application is for general information only AND is not tailored to the individual consumer

Jacobs A D, Ammerman A S, Ennett S T et al. Effects of a tailored follow-up intervention on health behaviors, beliefs, and attitudes. Journal of Women’s Health 2004;13(5):557–568

Study of a point of care device

Jansa M, Vidal M, Viaplana J et al. Telecare in a structured therapeutic education programme addressed to patients with type 1 diabetes and poor metabolic control. Diabetes Res Clin Pract 2006;74(1):26–32

Study of a point of care device

Jibaja-Weiss M L, Volk R J. Utilizing computerized entertainment education in the development of decision aids for lower literate and naive computer users. J Health Commun 2007;12(7):681–97

No health informatics application;

Other*

Jones J. Patient education and the use of the World Wide Web. Clin Nurse Spec 2003;17(6):281–3

Health informatics application is for general information only AND is not tailored to the individual consumer;

No original data

Jones R B, Atkinson J M, Coia D A et al. Randomised trial of personalised computer based information for patients with schizophrenia. BMJ 2001;322(7290):835–40

Health informatics application does not apply to the consumer

Jones R, Labajo R, Soler-Lopez Alonso et al. “Evaluation of a Scottish touch-screen public-access health information system in rural Spain.” In Current Perspectives in Healthcare Computing Conference, Harrogate 20–22 March 2000, 45–54. Guildford, UNITED KINGDOM: British Computer Society Health Informatics Committee, 2000

Health informatics application is for general information only AND is not tailored to the individual consumer

Jones R, Pearson J, Cawsey A et al. Information for patients with cancer. Does personalization make a difference? Pilot study results and randomised trial in progress. Proc AMIA Annu Fall Symp 96;423–7

No original data;

Not a RCT and not a study addressing barriers

Kaldo V, Levin S, Widarsson J et al. Internet versus group cognitive-behavioral treatment of distress associated with tinnitus: a randomized controlled trial. Behav Ther 2008;39(4):348–59

Health informatics application does not apply to the consumer;

Study of a point of care device

Kaphingst K A, Zanfini C J, Emmons K M. Accessibility of web sites containing colorectal cancer information to adults with limited literacy (United States). Cancer Causes Control 2006;17(2):147–51

Health informatics application is for general information only AND is not tailored to the individual consumer

Kaufman DR, Rockoff ML. Increasing access to online information about health: a program for inner-city elders in community-based organizations. Generations 2006;30(2):55–57

No original data

Kennedy M G, Kiken L, Shipman J P. Addressing underutilization of consumer health information resource centers: a formative study. J Med Libr Assoc 2008;96(1):42–9

No health informatics application;

Health informatics application is for general information only AND is not tailored to the individual consumer

Kenwright M, Liness S, Marks I. Reducing demands on clinicians by offering computer-aided self-help for phobia/panic. Feasibility study. Br J Psychiatry 2001;179456–9

Study of a point of care device;

Not a RCT, and not a study addressing barriers

Kerr C, Murray E, Stevenson F et al. Interactive health communication applications for chronic disease: patient and carer perspectives. J Telemed Telecare 2005;11 Suppl 132–4

No health informatics application;

Health informatics application is for general information only AND is not tailored to the individual consumer

Khoo K, Bolt P, Babl F E et al. Health information seeking by parents in the Internet age. J Paediatr Child Health 2008;44(7–8):419–23

Health informatics application does not apply to the consumer

Kim E H, Stolyar A, Lober W B et al. Usage patterns of a personal health record by elderly and disabled users. AMIA Annu Symp Proc 2007;409–13

Health informatics application does not apply to the consumer

Kim H S, Yoo Y S, Shim H S. Effects of an Internet-based intervention on plasma glucose levels in patients with type 2 diabetes. J Nurs Care Qual 2005;20(4):335–40

Health informatics application does not apply to the consumer;

Study of a point of care device

Kim J, Trace D, Meyers K et al. An empirical study of the Health Status Questionnaire System for use in patient-computer interaction. Proc AMIA Annu Fall Symp 97;86–90

Health informatics application does not apply to the consumer;

Health informatics application is for general information only AND is not tailored to the individual consumer

Kim S, Chung D S. Characteristics of cancer blog users. J Med Libr Assoc 2007;95(4):445–50

Health informatics application does not apply to the consumer;

Health informatics application is for general information only AND is not tailored to the individual consumer

King A C, Friedman R, Marcus B et al. Ongoing Physical Activity Advice by Humans Versus Computers: The Community Health Advice by Telephone (CHAT) Trial. Health Psychol. 2007;26(6):718–727

Other*

Kingston J. Web-based support for patients with type 2 diabetes in West Norfolk Primary Care Trust. A district model of diabetes care. Practical Diabetes International 2005;22(8):302

No original data

Kiropoulos L A, Klein B, Austin D W et al. Is internet-based CBT for panic disorder and agoraphobia as effective as face-to-face CBT?. J Anxiety Disord 2008;22(8):1273–84

Study of a point of care device;

Other*

Kiss G R, Walton H J, Farvis K M et al. An adaptive, on-line computer program for the exploration of attitude structures in psychiatric patients. Int J Biomed Comput 74;5(1):39–50

Study of a point of care device

Klein B, Richards J C, Austin D W. Efficacy of internet therapy for panic disorder. J Behav Ther Exp Psychiatry 2006;37(3):213–38

Study of a point of care device

Koivunen M, Hatonen H, Valimaki M. Barriers and facilitators influencing the implementation of an interactive Internet-portal application for patient education in psychiatric hospitals. Patient Educ Couns 2008;70(3):412–9

Health informatics application does not apply to the consumer

Koonce T Y, Giuse D A, Beauregard J M et al. Toward a more informed patient: bridging health care information through an interactive communication portal. J Med Libr Assoc 2007;95(1):77–81

Health informatics application is for general information only AND is not tailored to the individual consumer;

No original data

Kreuter M W, Strecher V J. Do tailored behavior change messages enhance the effectiveness of health risk appraisal? Results from a randomized trial. Health Education Research 96;11(1):97–105

No health informatics application

Krukowski R A, Harvey-Berino J, Ashikaga T et al. Internet-based weight control: the relationship between web features and weight loss. Telemed J E Health 2008;14(8):775–82

Other*

Kypri K, Langley J D, Saunders J B et al. Randomized controlled trial of web-based alcohol screening and brief intervention in primary care. Arch Intern Med 2008;168(5):530–6

Health informatics application does not apply to the consumer

Lai T Y, Larson E L, Rockoff M L et al. User acceptance of HIV TIDES--Tailored Interventions for Management of Depressive Symptoms in persons living with HIV/AIDS. J Am Med Inform Assoc 2008;15(2):217–26

Not a RCT, and not a study addressing barriers

Lange A, van de, Ven J P et al. Interapy, treatment of posttraumatic stress through the Internet: a controlled trial. J Behav Ther Exp Psychiatry 2001;32(2):73–90

Study of a point of care device

Lee C J. Does the internet displace health professionals?. J Health Commun 2008;13(5):450–64

Health informatics application does not apply to the consumer

Lee D M, Fairley C K, Sze J K et al. Access to sexual health advice using an automated, internet-based risk assessment service. Sex Health 2009;6(1):63–6

Other*

Legare F, Dodin S, Stacey D et al. Patient decision aid on natural health products for menopausal symptoms: randomized controlled trial. Menopause Int 2008;14(3):105–10

No health informatics application

Lemire M, Pare G, Sicotte C et al. Determinants of Internet use as a preferred source of information on personal health. Int J Med Inform 2008;77(11):723–34

No health informatics application;

Health informatics application is for general information only AND is not tailored to the individual consumer

Lemire M, Pare G, Sicotte C et al. Determinants of Internet use as a preferred source of information on personal health. Int J Med Inform 2008;77(11):723–34

No original data

Leong T Y, Aronsky D, Shabot M M. Computer-based decision support for critical and emergency care. J Biomed Inform 2008;41(3):409–12

No original data

Leung K Y, Lee C P, Chan H Y et al. Randomised trial comparing an interactive multimedia decision aid with a leaflet and a video to give information about prenatal screening for Down syndrome. Prenat Diagn 2004;24(8):613–8

Health informatics application does not apply to the consumer

Levetan C S, Dawn K R, Robbins D C et al. Impact of computer-generated personalized goals on HbA(1c). Diabetes care 2002;25(1):2–8

Other*

Lewis D, Gunawardena S, El Saadawi G. Caring connection: developing an Internet resource for family caregivers of children with cancer. Comput Inform Nurs 2005;23(5):265–74

Health informatics application is for general information only AND is not tailored to the individual consumer;

No original data

Liaw S T, Radford A J, Maddocks I. The impact of a computer generated patient held health record. Aust Fam Physician 98;27 Suppl 1S39–43

Health informatics application does not apply to the consumer;

Not a RCT, and not a study addressing barriers

Lim J E, Choi O H, Na H S et al. A context-aware fitness guide system for exercise optimization in U-health. IEEE Trans Inf Technol Biomed 2009;13(3):370–9

Health informatics application does not apply to the consumer;

Not a RCT, and not a study addressing barriers

Lim J E, Choi O H, Na H S et al. A context-aware fitness guide system for exercise optimization in U-health. IEEE Trans Inf Technol Biomed 2009;13(3):370–9

Other*

Lindsay S, Smith S, Bellaby P et al. The health impact of an online heart disease support group: a comparison of moderated versus unmoderated support. Health Educ Res 2009;24(4):646–54

No health informatics application;

Health informatics application is for general information only AND is not tailored to the individual consumer;

Other*

Linke S, Brown A, Wallace P. Down your drink: A web-based intervention for people with excessive alcohol consumption. Alcohol and Alcoholism 2004;39(1):29–32

Not a RCT, and not a study addressing barriers

Linke S, Murray E, Butler C et al. Internet-based interactive health intervention for the promotion of sensible drinking: Patterns of use and potential impact on members of the general public. Journal of Medical Internet Research 2007;9: e10

Not a RCT, and not a study addressing barriers

Lipkus I M, Rimer B K, Halabi S et al. Can tailored interventions increase mammography use among HMO women?. Am J Prev Med 2000;18(1):1–10

No health informatics application

Lorence D P, Greenberg L. The zeitgeist of online health search. Implications for a consumer-centric health system. J Gen Intern Med 2006;21(2):134–9

No health informatics application;

Health informatics application is for general information only AND is not tailored to the individual consumer

Lorence D, Park H. Group disparities and health information: a study of online access for the underserved. Health Informatics J 2008;14(1):29–38

Health informatics application is for general information only AND is not tailored to the individual consumer

Macdougall J. Community access to health information in Ireland. Health Libr Rev 99;16(2):89–96

No health informatics application;

Health informatics application does not apply to the consumer

Magee J C, Ritterband L M, Thorndike F P et al. Exploring the Relationship between Parental Worry about their Children’s Health and Usage of an Internet Intervention for Pediatric Encopresis. J Pediatr Psychol 2008;

Health informatics application does not apply to the consumer;

Other*

Mahabee-Gittens E M, Gordon J S, Krugh M E et al. A smoking cessation intervention plus proactive quitline referral in the pediatric emergency department: a pilot study. Nicotine Tob Res 2008;10(12):1745–51

No health informatics application;

Health informatics application is for general information only AND is not tailored to the individual consumer

Majumdar BB. The effectiveness of a culturally sensitive educational programme of self-perception of health, happiness, self-confidence, and loneliness in Southeast Asian seniors. 1995 (Doctoral Dissertation)

Other*

Malone M, Mathes L, Dooley J et al. Health information seeking and its effect on the doctor-patient digital divide. J Telemed Telecare 2005;11 Suppl 125–8

No health informatics application

Marceau L D, Link C, Jamison R N et al. Electronic diaries as a tool to improve pain management: is there any evidence?. Pain Med 2007;8 Suppl 3S101–9

Health informatics application is for general information only AND is not tailored to the individual consumer

Marcus B H, Lewis B A, Williams D M et al. Step into Motion: a randomized trial examining the relative efficacy of Internet vs. print-based physical activity interventions. Contemp Clin Trials 2007;28(6):737–47

Other*

Masucci M M, Homko C, Santamore W P et al. Cardiovascular disease prevention for underserved patients using the Internet: bridging the digital divide. Telemed J E Health 2006;12(1):58–65

Study of a point of care device

Matano R A, Koopman C, Wanat S F et al. A pilot study of an interactive web site in the workplace for reducing alcohol consumption. J Subst Abuse Treat 2007;32(1):71–80

No health informatics application;

Other*

Mattila E, Parkka J, Hermersdorf M et al. Mobile diary for wellness management--results on usage and usability in two user studies. IEEE Trans Inf Technol Biomed 2008;12(4):501–12

No original data

Mayben J K, Giordano T P. Internet use among low-income persons recently diagnosed with HIV infection. AIDS Care 2007;19(9):1182–7

Health informatics application does not apply to the consumer;

Health informatics application is for general information only AND is not tailored to the individual consumer

McClure L A, Harrington K F, Graham H et al. Internet-based monitoring of asthma symptoms, peak flow meter readings, and absence data in a school-based clinical trial. Clinical Trials 2008;5(1):31–37

Health informatics application does not apply to the consumer

McCoy M R, Couch D, Duncan N D et al. Evaluating an Internet weight loss program for diabetes prevention. Health Promotion International 2005;20(3):221–228

Not a RCT, and not a study addressing barriers;

Other*

McKee B. Electronic access to consumer health information.. Health Libraries Review 89;6(2):119–121

No original data

McMahon G T, Gomes H E, Hickson Hohne S et al. Web-based care management in patients with poorly controlled diabetes. Diabetes Care 2005;28(7):1624–9

Health informatics application does not apply to the consumer;

Study of a point of care device

McTavish F M, Pingree S, Hawkins R et al. Cultural differences in use of an electronic discussion group. Journal of Health Psychology 2003;8(1):105–117

Other*

Mead N, Varnam R, Rogers A et al. What predicts patients’ interest in the Internet as a health resource in primary care in England?. J Health Serv Res Policy 2003;8(1):33–9

Health informatics application is for general information only AND is not tailored to the individual consumer

Meingast M, Roosta T, Sastry S. Security and privacy issues with health care information technology. Conf Proc IEEE Eng Med Biol Soc 2006;15453–8

No health informatics application

Health informatics application does not apply to the consumer

Mennell S, Murcott A, van Otterloo A H. The sociology of food: eating, diet and culture. Sociology Abstracts 1992; Newbury Park, CA: Sage Publications

Other*

Mermelstein R, Turner L. Web-based support as an adjunct to group-based smoking cessation for adolescents. Nicotine Tob Res 2006;8 Suppl 1S69–76

Health informatics application does not apply to the consumer;

Study of a point of care device

Mitchell J E, Myers T, Swan-Kremeier L et al. Psychotherapy for bulimia nervosa delivered via telemedicine. European Eating Disorders Review 2003;11(3):222–230

Study of a point of care device;

Other*

Molenaar S, Sprangers M A, Postma-Schuit F C et al. Feasibility and effects of decision aids. Med Decis Making 2000;20(1):112–27

No original data

Montani S, Bellazzi R, Quaglini S et al. Meta-analysis of the effect of the use of computer-based systems on the metabolic control of patients with diabetes mellitus. Diabetes Technology and Therapeutics 2001;3(3):347–356

No original data

Montelius E, Astrand B, Hovstadius B et al. Individuals appreciate having their medication record on the web: a survey of attitudes to a national pharmacy register. J Med Internet Res 2008;10(4):e35

Health informatics application does not apply to the consumer;

Health informatics application is for general information only AND is not tailored to the individual consumer

Moore T J, Alsabeeh N, Apovian C M et al. Weight, blood pressure, and dietary benefits after 12 months of a Web-based Nutrition Education Program (DASH for health): longitudinal observational study. J Med Internet Res 2008;10(4):e52

Health informatics application is for general information only AND is not tailored to the individual consumer;

Not a RCT, and not a study addressing barriers

Moore T J, Alsabeeh N, Apovian C M et al. Weight, blood pressure, and dietary benefits after 12 months of a Web-based Nutrition Education Program (DASH for health): longitudinal observational study. J Med Internet Res 2008;10(4):e52

Other*

Moran W P, Nelson K, Wofford J L et al. Computer-generated mailed reminders for influenza immunization: a clinical trial. J Gen Intern Med 92;7(5):535–7

No health informatics application

Study of a point of care device

Mustafa Y. E-health centre: a web-based tool to empower patients to become proactive customers. Health Info Libr J 2004;21(2):129–33

No original data

Newton N C, Andrews G, Teesson M et al. Delivering prevention for alcohol and cannabis using the internet: a cluster randomised controlled trial. Prev Med 2009;48(6):579–84

Health informatics application is for general information only AND is not tailored to the individual consumer

Nguyen H Q, Carrieri-Kohlman V, Rankin S H et al. Is Internet-based support for dyspnea self-management in patients with chronic obstructive pulmonary disease possible? Results of a pilot study. Heart Lung 2005;34(1):51–62

Study of a point of care device

Nix S T, Ibanez C D, Strobino B A et al. Developing a computer-assisted health knowledge quiz for preschool children. Journal of School Health 99;69(1):9–11

Health informatics application does not apply to the consumer

Noell J, Glasgow R E. Interactive technology applications for behavioral counseling: Issues and opportunities for health care settings. American Journal of Preventive Medicine 99;17(4):269–274

No original data

Norman C D, Skinner H A. eHealth Literacy: Essential Skills for Consumer Health in a Networked World. J Med Internet Res 2006;8(2):e9

No original data

Norman C. CATCH-IT Report: Evaluation of an Internet-based smoking cessation program: Lessons learned from a pilot study. Journal of Medical Internet Research 2004;6(4)

No original data

Nwosu CR, Cox BM. The impact of the Internet on the doctor-patient relationship.. Health Informatics Journal 2000;6(3):156–161

No health informatics application

O’Connor A M, Rostom A, Fiset V et al. Decision aids for patients facing health treatment or screening decisions: systematic review. BMJ 99;319(7212):731–4

No original data;

Not a RCT, and not a study addressing barriers

Oenema A, Brug J. Feedback strategies to raise awareness of personal dietary intake: Results of a randomized controlled trial. Preventive Medicine 2003;36(4):429–439

Other*

Olver I N, Whitford H S, Denson L A et al. Improving informed consent to chemotherapy: a randomized controlled trial of written information versus an interactive multimedia CD-ROM. Patient Educ Couns 2009;74(2):197–204

Other*

Ornstein S M, Garr D R, Jenkins R G et al. Computer-generated physician and patient reminders. Tools to improve population adherence to selected preventive services. J Fam Pract 91;32(1):82–90

Study of a point of care device

Osman L M, Abdalla M I, Beattie J A et al. Reducing hospital admission through computer supported education for asthma patients. Grampian Asthma Study of Integrated Care (GRASSIC). BMJ 94;308(6928):568–71

No health informatics application

Otsuki M. Social connectedness and smoking behaviors among Asian American college students: An electronic diary study. Nicotine Tob Res 2009;11(4):418–26

No health informatics application;

Other*

Papadaki A, Scott J A. Follow-up of a web-based tailored intervention promoting the Mediterranean diet in Scotland. Patient Educ Couns 2008;73(2):256–63

Not a RCT, and not a study addressing barriers;

Other*

Parlove AE, Cowdery JE, Hoerauf SL. Acceptability and appeal of a Web-based smoking prevention intervention for adolescents.. International Electronic Journal of Health Education 2004;71–8

No health informatics application;

Other*

Partin M R, Nelson D, Flood A B et al. Who uses decision aids? Subgroup analyses from a randomized controlled effectiveness trial of two prostate cancer screening decision support interventions. Health Expect 2006;9(3):285–95

No health informatics application

Patrick K, Raab F, Adams M A et al. A text message-based intervention for weight loss: randomized controlled trial. J Med Internet Res 2009;11(1):e1

Health informatics application is for general information only AND is not tailored to the individual consumer;

Other*

Patten C A, Rock E, Meis T M et al. Frequency and type of use of a home-based, Internet intervention for adolescent smoking cessation. J Adolesc Health 2007;41(5):437–43

Health informatics application is for general information only AND is not tailored to the individual consumer;

Other*

Penn DL, Simpson LE, Leggett S et al. The development of a Web site to promote the mental and physical health of sons and daughters of Vietnam veterans of Australia.. Journal of Consumer Health on the Internet 2006;10(4):45–63

Health informatics application is for general information only AND is not tailored to the individual consumer

Pennbridge J, Moya R, Rodrigues L. Questionnaire survey of California consumers’ use and rating of sources of health care information including the Internet. West J Med 99;171(5–6):302–5

Health informatics application is for general information only AND is not tailored to the individual consumer;

Other*

Pingree S, Hawkins R P, Gustafson D H et al. Will HIV-positive people use an interactive computer system for information and support? A study of CHESS in two communities. Proc Annu Symp Comput Appl Med Care 93;22–6

Study of a point of care device

Plotnikoff R C, McCargar L J, Wilson P M et al. Efficacy of an e-mail intervention for the promotion of physical activity and nutrition behavior in the workplace context. American Journal of Health Promotion 2005;19(6):422–429

No health informatics application

Polzien K M, Jakicic J M, Tate D F et al. The efficacy of a technology-based system in a short-term behavioral weight loss intervention. Obesity (Silver Spring) 2007;15(4):825–30

No health informatics application;

Study of a point of care device

Port K, Palm K, Viigimaa M. Daily usage and efficiency of remote home monitoring in hypertensive patients over a one-year period. J Telemed Telecare 2005;11 Suppl 134–6

No health informatics application

Porter S C, Silvia M T, Fleisher G R et al. Parents as direct contributors to the medical record: validation of their electronic input. Ann Emerg Med 2000;35(4):346–52

No health informatics application;

Health informatics application does not apply to the consumer

Prochaska J O, Velicer W F, Redding C et al. Stage-based expert systems to guide a population of primary care patients to quit smoking, eat healthier, prevent skin cancer, and receive regular mammograms. Prev Med 2005;41(2):406–16

No health informatics application

Proudfoot J, Swain S, Widmer S et al. The development and beta-test of a computer-therapy program for anxiety and depression: Hurdles and lessons. 2003;19(3):277–289

Not a RCT, and not a study addressing barriers;

Other*

Quinn P, Goka J, Richardson H. Assessment of an electronic daily diary in patients with overactive bladder. BJU Int 2003;91(7):647–52

No health informatics application

Ralston J D, Hirsch I B, Hoath J et al. Web-based collaborative care for type 2 diabetes: a pilot randomized trial. Diabetes Care 2009;32(2):234–9

Study of a point of care device

Ran D, Peretz B. Assessing the pain reaction of children receiving periodontal ligament anesthesia using a computerized device (Wand). J Clin Pediatr Dent 2003;27(3):247–50

No health informatics application;

Study of a point of care device

Raphael C, Cornwell J L. Influencing support for caregivers. Am J Nurs 2008;108(9 Suppl):78–82; quiz 82

No health informatics application;

No original data

Recabarren M, Nussbaum M, Leiva C. Cultural illiteracy and the Internet. Cyberpsychol Behav 2007;10(6):853–6

No health informatics application

Renahy E, Parizot I, Chauvin P. Health information seeking on the Internet: a double divide? Results from a representative survey in the Paris metropolitan area, France, 2005–2006. BMC Public Health 2008;869

Health informatics application is for general information only AND is not tailored to the individual consumer

Resnik D B. Patient access to medical information in the computer age: ethical concerns and issues. Camb Q Healthc Ethics 2001;10(2):147–54; discussion 154–6

No health informatics application;

No original data

Rigby M, Draper R, Hamilton I. Finding ethical principles and practical guidelines for the controlled flow of patient data. Methods Inf Med 99;38(4–5):345–9

No health informatics application;

No original data

Rizo C A, Lupea D, Baybourdy H et al. What Internet services would patients like from hospitals during an epidemic? Lessons from the SARS outbreak in Toronto. J Med Internet Res 2005;7(4):e46

Health informatics application is for general information only AND is not tailored to the individual consumer;

Study of a point of care device

Rogers J L, Haring O M, Goetz J P. Changes in patient attitudes following the implementation of a medical information system. QRB Qual Rev Bull 84;10(3):65–74

Health informatics application does not apply to the consumer;

Study of a point of care device

Rosenman S J, Levings C T, Korten A E. Clinical utility and patient acceptance of the computerized Composite International Diagnostic Interview. Psychiatr Serv 97;48(6):815–20

Study of a point of care device

Ross S E, Nowels C T, Haverhals L M et al. Qualitative assessment of Diabetes-STAR: a patient portal with disease management functions. AMIA Annu Symp Proc 2007;1097

No original data;

Other*

Rosser W W, Hutchison B G, McDowell I et al. Use of reminders to increase compliance with tetanus booster vaccination. CMAJ 92;146(6):911–7

No health informatics application;

Study of a point of care device

Rothert K, Strecher V J, Doyle L A et al. Web-based weight management programs in an integrated health care setting: a randomized, controlled trial. Obesity (Silver Spring) 2006;14(2):266–72

Study of a point of care device

Rotondi A J, Sinkule J, Spring M. An interactive Web-based intervention for persons with TBI and their families: use and evaluation by female significant others. J Head Trauma Rehabil 2005;20(2):173–85

Health informatics application is for general information only AND is not tailored to the individual consumer

Rovniak L S, Hovell M F, Wojcik J R et al. Enhancing theoretical fidelity: An e-mail-based walking program demonstration. American Journal of Health Promotion 2005;20(2):85–95

No health informatics application

Rozmovits L, Ziebland S. What do patients with prostate or breast cancer want from an Internet site? A qualitative study of information needs. Patient Educ Couns 2004;53(1):57–64

Health informatics application is for general information only AND is not tailored to the individual consumer

Rybarczyk B, Lopez M, Schelble K et al. Home-based video CBT for comorbid geriatric insomnia: a pilot study using secondary data analyses. Behav Sleep Med 2005;3(3):158–75

No health informatics application

Saitz R, Helmuth E D, Aromaa S E et al. Web-based screening and brief intervention for the spectrum of alcohol problems. Preventive Medicine 2004;39(5):969–975

Not a RCT, and not a study addressing barriers

Schinke S, Di Noia J, Schwinn T et al. Drug abuse risk and protective factors among black urban adolescent girls: a group-randomized trial of computer-delivered mother-daughter intervention. Psychol Addict Behav 2006;20(4):496–500

Health informatics application does not apply to the consumer;

Health informatics application is for general information only AND is not tailored to the individual consumer

Schinke S, Schwinn T. Gender-specific computer-based intervention for preventing drug abuse among girls. Am J Drug Alcohol Abuse 2005;31(4):609–16

No health informatics application;

Health informatics application is for general information only AND is not tailored to the individual consumer

Schmidt R, Norgall T, Morsdorf J et al. Body Area Network BAN--a key infrastructure element for patient-centered medical applications. Biomed Tech (Berl) 2002;47 Suppl 1 Pt 1365–8

No original data;

Other*

Schumann A, John U, Ulbricht S et al. Computer-generated tailored feedback letters for smoking cessation: theoretical and empirical variability of tailoring. Int J Med Inform 2008;77(11):715–22

No original data;

Other*

Scott C, Byng S. Computer assisted remediation of a homophone comprehension disorder in surface dyslexia. Aphasiology 89;3(3):301–320

Health informatics application does not apply to the consumer;

Not a RCT and not a study addressing barriers;

Other*

Secnik K, Pathak D S, Cohen J M. Postcard and telephone reminders for unclaimed prescriptions: a comparative evaluation using survival analysis. J Am Pharm Assoc (Wash) 2000;40(2):243–51; quiz 330–1

No health informatics application;

Health informatics application does not apply to the consumer

Seematter-Bagnoud L, Santos-Eggimann B. Sources and level of information about health issues and preventive services among young-old persons in Switzerland. Int J Public Health 2007;52(5):313–6

No health informatics application;

Health informatics application is for general information only AND is not tailored to the individual consumer

Shachak A, Shuval K, Fine S. Barriers and enablers to the acceptance of bioinformatics tools: a qualitative study. J Med Libr Assoc 2007;95(4):454–8

Health informatics application does not apply to the consumer

Shah A, Kuo A, Zurakowski D et al. Use and satisfaction of the internet in obtaining information on brachial plexus birth palsies and its influence on decision-making. J Pediatr Orthop 2006;26(6):781–4

No health informatics application;

Health informatics application is for general information only AND is not tailored to the individual consumer

Shaw M J, Beebe T J, Tomshine P A et al. A randomized, controlled trial of interactive, multimedia software for patient colonoscopy education. Journal of Clinical Gastroenterology 2001;32(2):142–147

Health informatics application is for general information only AND is not tailored to the individual consumer

Shepperd S, Charnock D, Gann B. Helping patients access high quality health information. BMJ 99;319(7212):764–6

No original data

Shigaki C L, Smarr K L, Yang Gong et al. Social interactions in an online self-management program for rheumatoid arthritis. Chronic Illn 2008;4(4):239–46

Other*

Silvia K A, Ozanne E M, Sepucha K R. Implementing breast cancer decision aids in community sites: barriers and resources. Health Expect 2008;11(1):46–53

Health informatics application does not apply to the consumer

Simoes A A, Bastos F I, Moreira R I et al. Acceptability of audio computer-assisted self-interview (ACASI) among substance abusers seeking treatment in Rio de Janeiro, Brazil. Drug Alcohol Depend 2006;82 Suppl 1S103–7

Health informatics application does not apply to the consumer

Siva C, Smarr K L, Hanson K D et al. Internet use and e-mail communications between patients and providers: a survey of rheumatology outpatients. J Clin Rheumatol 2008;14(6):318–23

Health informatics application does not apply to the consumer;

Other*

Skinner C S, Strecher V J, Hospers H. Physicians’ recommendations for mammography: Do tailored messages make a difference? American Journal of Public Health 94;84(1):43–49

No health informatics application

Skinner H, Morrison M, Bercovitz K et al. Using the Internet to engage youth in health promotion.

Promotion & education 1997;4(4):23–25

Health informatics application does not apply to the consumer;

Health informatics application is for general information only AND is not tailored to the individual consumer

Smaglik P, Hawkins R P, Pingree S et al. The quality of interactive computer use among HIV-infected individuals. Journal of Health Communication 1998;3(1):53–68

Not a RCT, and not a study addressing barriers;

Other*

Smith D T, Carr L J, Dorozynski C et al. Internet-delivered lifestyle physical activity intervention: limited inflammation and antioxidant capacity efficacy in overweight adults. J Appl Physiol 2009;106(1):49–56

Other*

Spallek H, Butler B S, Schleyer T K et al. Supporting emerging disciplines with e-communities: needs and benefits. J Med Internet Res 2008;10(2):e19

Health informatics application does not apply to the consumer

Staccini P, Joubert M, Fieschi D et al. Confidentiality issues within a clinical information system: moving from data-driven to event-driven design. Methods Inf Med 99;38(4–5):298–302

No health informatics application;

Health informatics application does not apply to the consumer

Staccini P, Joubert M, Fieschi D et al. Confidentiality issues within a clinical information system: moving from data-driven to event-driven design. Methods Inf Med 99;38(4–5):298–302

No original data

Steele R, Mummery W K, Dwyer T. Using the Internet to promote physical activity: a randomized trial of intervention delivery modes. J Phys Act Health 2007;4(3):245–60

No health informatics application;

Study of a point of care device

Stevens V J, Glasgow R E, Toobert D J et al. One-year results from a brief, computer-assisted intervention to decrease consumption of fat and increase consumption of fruits and vegetables. Prev Med 2003;36(5):594–600

Study of a point of care device

Stock S E, Davies D K, Davies K R et al. Evaluation of an application for making palmtop computers accessible to individuals with intellectual disabilities. J Intellect Dev Disabil 2006;31(1):39–46

No health informatics application

Stoddard J L, Augustson E M, Moser R P. Effect of adding a virtual community (bulletin board) to smokefree.gov: randomized controlled trial. J Med Internet Res 2008;10(5):e53

Health informatics application is for general information only AND is not tailored to the individual consumer

Stoddard J L, Delucchi K L, Munoz R F et al. Smoking cessation research via the internet: A feasibility study. Journal of Health Communication 2005;10(1):27–41

Not a RCT and not a study addressing barriers;

Other*

Strecher V J, Kreuter M, Den Boer et al. The effects of computer-tailored smoking cessation messages in family practice settings. Journal of Family Practice 1994;39(3):262–270

No health informatics application;

Other*

Strom L, Pettersson R, Andersson G. Internet-based treatment for insomnia: a controlled evaluation. J Consult Clin Psychol 2004;72(1):113–20

No health informatics application;

Study of a point of care device

Suggs L S, McIntyre C. Are We There Yet? An Examination of Online Tailored Health Communication. Health Educ Behav 2007;

No health informatics application;

Health informatics application is for general information only AND is not tailored to the individual consumer

Svetkey L P, Stevens V J, Brantley P J et al. Comparison of strategies for sustaining weight loss: the weight loss maintenance randomized controlled trial. JAMA 2008;299(10):1139–48

Study of a point of care device

Takahashi Y, Satomura K, Miyagishima K et al. A new smoking cessation programme using the Internet. Tobacco Control 1999;8(1):109–110

Study of a point of care device;

No original data

Tan R L. Medicare beneficiaries’’ use of computers and Internet: 1998–2005. Health Care Financing Review 2007;28(2):45–51

Health informatics application is for general information only AND is not tailored to the individual consumer

Tate D F, Wing R R, Winett R A. Using Internet technology to deliver a behavioral weight loss program. JAMA 2001;285(9):1172–7

Study of a point of care device

Taub S J. The Internet’s role in patient/physician interaction: bringing our understanding in line with online reality. Compr Ophthalmol Update 2006;7(1):25–30

No original data

Taylor D P, Bray B E, Staggers N et al. User-centered development of a Web-based preschool vision screening tool. AMIA Annu Symp Proc 2003;654–8

Other*

Ten Wolde G B, Dijkstra A, van Empelen P et al. Long-term effectiveness of computer-generated tailored patient education on benzodiazepines: a randomized controlled trial. Addiction 2008;103(4):662–70

Study of a point of care device

Tetzlaff L. Consumer informatics in chronic illness. J Am Med Inform Assoc 97;4(4):285–300

No health informatics application;

Health informatics application is for general information only AND is not tailored to the individual consumer;

Other*

Thobaben M. Technology and informatics. Accessibility, quality, and readability of health information on the internet: implication for home health care professionals.. Home Health Care Management & Practice 2002;14(4):295–296

Health informatics application does not apply to the consumer;

No original data

Thompson D, Baranowski T, Cullen K et al. Food, fun, and fitness internet program for girls: pilot evaluation of an e-Health youth obesity prevention program examining predictors of obesity. Prev Med 2008;47(5):494–7

Health informatics application is for general information only AND is not tailored to the individual consumer

Tiller K, Meiser B, Gaff C et al. A randomized controlled trial of a decision aid for women at increased risk of ovarian cancer. Med Decis Making 2006;26(4):360–72

No health informatics application

Titov N, Andrews G, Choi I et al. Shyness 3: randomized controlled trial of guided versus unguided Internet-based CBT for social phobia. Aust N Z J Psychiatry 2008;42(12):1030–40

Other*

Tjora A, Tran T, Faxvaag A. Privacy vs usability: a qualitative exploration of patients’ experiences with secure Internet communication with their general practitioner. J Med Internet Res 2005;7(2):e15

No health informatics application;

Health informatics application is for general information only AND is not tailored to the individual consumer;

Study of a point of care device

Torsney K. Advantages and disadvantages of telerehabilitation for persons with neurological disabilities. NeuroRehabilitation 2003;18(2):183–185

No original data

Tsang M W, Mok M, Kam G et al. Improvement in diabetes control with a monitoring system based on a hand-held, touch-screen electronic diary. J Telemed Telecare 2001;7(1):47–50

Not a RCT, and not a study addressing barriers;

Other*

Tugwell P S, Santesso N A, O’Connor A M et al. Knowledge translation for effective consumers. Phys Ther 2007;87(12):1728–38

No health informatics application;

Other*

Tuil W S, Verhaak C M, Braat D D et al. Empowering patients undergoing in vitro fertilization by providing Internet access to medical data. Fertil Steril 2007;88(2):361–8

No health informatics application;

Health informatics application does not apply to the consumer

Underhill C, Mckeown L. Getting a second opinion: health information and the Internet. Health Rep 2008;19(1):65–9

Health informatics application is for general information only AND is not tailored to the individual consumer

van den, Berg M H, Ronday H K et al. Using internet technology to deliver a home-based physical activity intervention for patients with rheumatoid arthritis: A randomized controlled trial. Arthritis Rheum 2006;55(6):935–45

Study of a point of care device

van der, Meer V, van Stel H F et al. Internet-based self-management offers an opportunity to achieve better asthma control in adolescents. Chest 2007;132(1):112–9

Study of a point of care device

Van Voorhees B W, Fogel J, Reinecke M A et al. Randomized clinical trial of an Internet-based depression prevention program for adolescents (Project CATCH-IT) in primary care: 12-week outcomes. J Dev Behav Pediatr 2009;30(1):23–37

Other*

van Wier M F, Ariens G A, Dekkers J C et al. Phone and e-mail counselling are effective for weight management in an overweight working population: a randomized controlled trial. BMC Public Health 2009;96

Other*

van Zutphen M, Milder I E, Bemelmans W J. Integrating an eHealth program for pregnant women in midwifery care: a feasibility study among midwives and program users. J Med Internet Res 2009;11(1):e7

Not a RCT, and not a study addressing barriers

Vandelanotte C, De Bourdeaudhuij I, Brug J. Acceptability and feasibility of an interactive computer-tailored fat intake intervention in Belgium. Health Promotion Internation 2004;19(4):463–470

Not a RCT, and not a study addressing barriers;

Other*

Wade SL, Wolfe CR, Brown TM et al. Can a Web-based family problem-solving intervention work for children with traumatic brain injury?. Rehabilitation Psychology 2005;50(4):337–345

No health informatics application;

Health informatics application does not apply to the consumer

Wagner T H, Greenlick M R. When parents are given greater access to health information, does it affect pediatric utilization?. Med Care 2001;39(8):848–55

No health informatics application;

Not a RCT, and not a study addressing barriers

Walker S N, Pullen C H, Boeckner L et al. Clinical trial of tailored activity and eating newsletters with older rural women. Nurs Res 2009;58(2):74–85

No health informatics application

Wantland D. Content and Functional Assessment of A HIV/AIDS Tailored Web-Based Symptom Self Assessment and Self Management Tool. Stud Health Technol Inform 2009;146820–1

Health informatics application does not apply to the consumer

Wantland D. Content and Functional Assessment of A HIV/AIDS Tailored Web-Based Symptom Self Assessment and Self Management Tool. Stud Health Technol Inform 2009;146820–1

Other*

Warmerdam L, van Straten A, Cuijpers P. Internet-based treatment for adults with depressive symptoms: the protocol of a randomized controlled trial. BMC Psychiatry 2007;772

Study of a point of care device

Weinert C, Cudney S, Hill W. Retention in a computer-based outreach intervention for chronically ill rural women. Appl Nurs Res 2008;21(1):23–9

Health informatics application is for general information only AND is not tailored to the individual consumer;

Study of a point of care device

Weingart S N, Rind D, Tofias Z et al. Who uses the patient internet portal? The PatientSite experience. J Am Med Inform Assoc 2006;13(1):91–5

Health informatics application does not apply to the consumer;

Health informatics application is for general information only AND is not tailored to the individual consumer

What children think about computers. Future Child 2000;10(2):186–91

No health informatics application;

Health informatics application is for general information only AND is not tailored to the individual consumer

White M A, Martin P D, Newton R L et al. Mediators of weight loss in a family-based intervention presented over the internet. Obes Res 2004;12(7):1050–9

Health informatics application is for general information only AND is not tailored to the individual consumer

White M. Enhancing process efficiency through remote access. Wireless implementation and remote access enable medical oncology practice to improve patient and clinician confidence while achieving ROI. Health Manag Technol 2004;25(3):42–3

No original data

Whitten P, Mickus M. Home telecare for COPD/CHF patients: outcomes and perceptions. J Telemed Telecare 2007;13(2):69–73

Study of a point of care device

Williams A. Surfing over sixty. Making Internet access available helps residents stay connected. Provider 99;25(8):69, 71–2

No original data

Williams G C, Lynch M, Glasgow R E. Computer-assisted intervention improves patient-centered diabetes care by increasing autonomy support. Health Psychol 2007;26(6):728–34

Other*

Williams M L, Freeman R C, Bowen A M et al. The acceptability of a computer HIV/AIDS risk assessment to not-in-treatment drug users. AIDS Care 98;10(6):701–11

Study of a point of care device

Williams R B, Boles M, Johnson R E. A patient-initiated system for preventive health care. A randomized trial in community-based primary care practices. Arch Fam Med 98;7(4):338–45

Health informatics application does not apply to the consumer;

Study of a point of care device

Wilson C, Flight I, Hart E et al. Internet access for delivery of health information to South Australians older than 50. Aust N Z J Public Health 2008;32(2):174–6

Health informatics application is for general information only AND is not tailored to the individual consumer;

Other*

Wilson E V, Lankton N K. Modeling patients’ acceptance of provider-delivered e-health. J Am Med Inform Assoc 2004;11(4):241–8

Health informatics application is for general information only AND is not tailored to the individual consumer

Wilson P. Searching for the needle in the haystack -- or -- quality criteria for health-related websites.. Health IT Advisory Report 2001;3(1):20–23

Health informatics application is for general information only AND is not tailored to the individual consumer

Wilson-Steele G. Improving healthcare through patient education, patient relationship management. Internet Healthc Strateg 2003;5(3):8

Study of a point of care device;

No original data

Winett R A, Anderson E S, Wojcik J R et al. Guide to health: nutrition and physical activity outcomes of a group-randomized trial of an Internet-based intervention in churches. Ann Behav Med 2007;33(3):251–61

Health informatics application does not apply to the consumer

Wong B M, Yung B M, Wong A et al. Increasing Internet use among cardiovascular patients: new opportunities for heart health promotion. Can J Cardiol 2005;21(4):349–54

Health informatics application is for general information only AND is not tailored to the individual consumer

Woolf S H, Krist A H, Johnson R E et al. A practice-sponsored Web site to help patients pursue healthy behaviors: an ACORN study. Ann Fam Med 2006;4(2):148–52

Other*

Wright J H, Wright A S, Albano A M et al. Computer-assisted cognitive therapy for depression: maintaining efficacy while reducing therapist time. Am J Psychiatry 2005;162(6):1158–64

No health informatics application;

Study of a point of care device

Zanchetta MS. Understanding functional health literacy in experiences with prostate cancer: older men as consumers of health information.. Online Brazilian Journal of Nursing 2004;3(2):9p

Health informatics application is for general information only AND is not tailored to the individual consumer

List of “other” reasons:

1. Based on data from 2 other trials
2. Book
3. Case study
4. Chess discussion board
5. Cohort study, no control group, no comparison to other methods of testing hearing
6. Commentary--not a study no info
7. Comparing paper based consent form with cd-rom, no tailored info
8. Contact with therapist
9. Contains learning modules only--no tailoring
10. Data not abstractable
11. Description and pilot test
12. Description of the system
13. Development study
14. Development survey
15. Discussion board
16. Doctoral dissertation
17. Electronic diaries only to measure. The study does not examine its impact.
18. Evaluate an internet-based hearing test, no control grp
19. Evaluate the use of a computerized concept for lifestyle
20. Evaluation
21. Focus group--does not address any real barriers
22. Group therapy, no tailored, therapist presence
23. It seems to talk more on lines with group discussion and moderation of group.
24. Descriptive
25. No data comparing experimental and control group; no barriers nor facilitators
26. No data--usage study
27. No health outcomes, just a satisfaction assessment with the system
28. No outcome data available
29. No quantitative data are reported
30. No result
31. No tailored information provided to patients from this application, only to physicians
32. No tailoring required
33. No usable data
34. No usable outcomes, and i really don’t think this is a tailored in tailored out study
35. Not about the application but about the parent
36. Not computerized tailored
37. Not tailored and can not isolate the impact of the application from impact of the community chat
38. Not tailored and intervention includes human counseling
39. Not tailored or interactive
40. Not tailored, and there was clinician interaction
41. Only abstract
42. Output is not applied to the patient
43. Overview of a type of full-body sensor
44. Participants had no access to application
45. Patient-centered care
46. Pilot testing of the instrument. Does not look like a study
47. Presence of health care provider -web-based tool to help people to manage their health and improve their communication with their health care provide
48. Qualitative analysis of website usage; does not provide barriers nor facilitators
49. Survey on access to the internet
50. Survey on general use
51. Tailoring not required
52. Tailoring occurs at the level of chat group and therapist
53. Tailoring was accomplished in this study by providing flexibility in the number and timing of receipt of message each day.
54. Telecommunication
55. Telemedicine
56. This is a pilot beta-test
57. This is a study of “use” not any real outcomes
58. Usage study
59. Video informed consent
60. Web based management of diabetes, physician presence
61. Web-based intervention with e-mail counseling
62. Website rating
63. Workplace