# Appendix D Grey Literature Detailed Search Strategies

Database | Terms
Health Services Research Projects in Progress | (((informatics OR internet OR consumer health information) AND (consumer OR patients OR parents OR caregivers) AND (randomized controlled trial OR clinical trial)) OR ((informatics OR internet OR consumer health information) AND (consumer OR patients OR parents OR caregivers) AND (access OR barrier OR facilitator OR compatibility OR user centered)))
IEEE CNF IEEE Conference Proceeding IET CNF IET Conference Proceeding | ((((((informatics or internet or consumer health information) and (consumer or patients or parents or caregivers) and (randomized controlled trial or clinical trial)) or ((informatics or internet or consumer health information) and (consumer or patients or parents or caregivers) and (access or barrier or facilitator or compatibility or user centered))))<in>metadata)) <and> (pyr >= 1990 <and> pyr <= 2009)
Proceedings of the American Society for Information Science and Technology (Wiley InterScience) | informatics OR “health information” OR “consumer health information” OR internet
WHO –International Clinical Trials Registry Platform | informatics applications OR consumer health information OR internet
American Public Health Association (APHA) 2000-2008 | Consumer health information OR health information OR consumer
OpenSIGLE - System for Information on Grey Literature in Europe | (((informatics OR internet OR consumer health information) AND (consumer OR patients OR parents OR caregivers) AND (randomized controlled trial OR clinical trial)) OR ((informatics OR internet OR consumer health information) AND (consumer OR patients OR parents OR caregivers) AND (access OR barrier OR facilitator OR compatibility OR user centered)))
The New York Academy of Medicine – Grey Literature | informatics OR "consumer health information" OR "health info rmation application"