# Appendix C Detailed Search Strategies

Database | Terms | Date | Returns
PubMed | ((("Medical Informatics Applications"[Mesh] OR "Informatics"[Mesh] OR "medical informatics"[mh] OR telemedicine[mh] OR informatics[tiab] OR internet[tiab] OR internet[mh] OR "Consumer Health Information"[Mesh] OR "Support systems"[tiab]) AND (consumer[tiab] OR "Patients"[Mesh] OR patients[tiab] OR patient[tiab] OR parents[mh] OR parents[tiab] OR parent[tiab] OR "age groups"[mh] OR Caregivers[mh] OR caregiver[tiab] OR "care giver"[tiab] OR "persons"[mh] OR persons[tiab] OR person[tiab] OR people[tiab] OR individual[tiab] OR individuals[tiab]) AND English[lang] AND ("randomized controlled trial"[pt] OR "randomized controlled trials as topic"[mh] OR "randomized controlled trial"[tiab] OR "randomised controlled trial"[tiab] OR "controlled trial"[tiab] OR "clinical trial"[tiab]) NOT (editorial[pt] OR letter[pt] OR comment[pt]) NOT (animal[mh] NOT human[mh]) AND (("1900/01/01"[PDat] : "2009/06/01"[PDat]))) OR (("Medical Informatics Applications"[Mesh] OR "Informatics"[Mesh] OR "medical informatics"[mh] OR telemedicine[mh] OR informatics[tiab] OR internet[tiab] OR "internet"[MeSH Terms] OR "Consumer Health Information"[Mesh] OR "Support systems"[tiab]) AND (consumer[tiab] OR "Patients"[Mesh] OR patients[tiab] OR patient[tiab] OR "parents"[MeSH Terms] OR parents[tiab] OR parent[tiab] OR "age groups"[mh] OR "caregivers"[MeSH Terms] OR caregiver[tiab] OR "care giver"[tiab] OR "persons"[mh] OR persons[tiab] OR person[tiab] OR people[tiab] OR individual[tiab] OR individuals[tiab]) AND (Access[tiab] OR barrier[tiab] OR facilitator[tiab] OR compatibility[tiab] OR incompatibility[tiab] OR "user-centered"[tiab] OR "user centered"[tiab] OR "work flow"[tiab] OR workflow[tiab] OR "reimbursement mechanisms"[mh] OR reimbursement[tiab] OR "attitude to computers"[mh] OR attitude[tiab] OR "health knowledge, attitudes, practice"[mh] OR "computer literacy"[mh] OR (computer[tiab] AND literacy[tiab])) AND English[lang] NOT (editorial[pt] OR letter[pt] OR comment[pt]) NOT ("animals"[MeSH Terms] NOT "humans"[MeSH Terms]) AND (("1900/01/01"[PDat] : "2009/06/01"[PDat]))) AND (("1900/01/01"[PDat] : "2009/06/01"[PDat]))) | June 1st, 2009 | 14561
EMBASE | (('informatics':ti,ab OR telemedicine:ti,ab OR internet:ti,ab OR 'consumer health information':ti,ab) AND (consumer:ti,ab OR 'patients':ti,ab OR parents:ti,ab OR 'age groups':ti,ab OR caregivers:ti,ab) AND ('randomized controlled trial':ti,ab OR (controlled:ti,ab AND trial:ti,ab) OR (clinical:ti,ab AND trial:ti,ab))) OR (('informatics':ti,ab OR telemedicine:ti,ab OR internet:ti,ab OR 'consumer health information':ti,ab) AND (consumer:ti,ab OR 'patients':ti,ab OR parents:ti,ab OR 'age groups':ti,ab OR caregivers:ti,ab) AND (access:ti,ab OR barrier:ti,ab OR facilitator:ti,ab OR compatibility:ti,ab OR incompatibility:ti,ab OR 'user centered':ti,ab OR 'work flow':ti,ab OR reimbursement:ti,ab OR attitude:ti,ab OR (computer:ti,ab AND literacy:ti,ab))) AND ([article]/lim OR [editorial]/lim OR [review]/lim) AND [english]/lim AND [humans]/lim | | 1421
Cochrane Library | (("Medical Informatics applications":ti,ab,kw or "Informatics":ti,ab,kw or (telemedicine):ti,ab,kw or (internet):ti,ab,kw or "Consumer Health Information":ti,ab,kw or “Support systems”:ti,ab,kw) AND ((consumer):ti,ab,kw or "Patients":ti,ab,kw or (parents):ti,ab,kw or "age groups":ti,ab,kw or (Caregivers):ti,ab,kw) AND ((randomized controlled trial):ti,ab,kw or (controlled trial):ti,ab,kw or (clinical trial):ti,ab,kw)) OR (("Medical Informatics applications":ti,ab,kw or "Informatics":ti,ab,kw or (telemedicine):ti,ab,kw or (internet):ti,ab,kw or "Consumer Health Information":ti,ab,kw or “Support systems”:ti,ab,kw) AND ((consumer):ti,ab,kw or "Patients":ti,ab,kw or (parents):ti,ab,kw or "age groups":ti,ab,kw or (Caregivers):ti,ab,kw) AND ((Access):ti,ab,kw or (barrier):ti,ab,kw or (facilitator):ti,ab,kw or (compatibility):ti,ab,kw or (incompatibility):ti,ab,kw or "user centered":ti,ab,kw or "work flow":ti,ab,kw or Reimbursement:ti,ab,kw or "attitude to computers":ti,ab,kw or “computer literacy”:ti,ab,kw)) | | 3716
SCOPUS | ((TITLE-ABS-KEY("Medical Informatics applications") OR TITLE-ABS- KEY(telemedicine) OR TITLE-ABS-KEY(internet) OR TITLE-ABS- KEY("Consumer Health Information")) AND (TITLE-ABS-KEY(consumer) OR TITLE-ABS-KEY("Patients") OR TITLE-ABS-KEY(caregivers)) AND (TITLE-ABS-KEY("randomized controlled trial") OR TITLE-ABS- KEY(“clinical trial”))) OR ((TITLE-ABS-KEY("Medical Informatics applications") OR TITLE-ABS-KEY(telemedicine) OR TITLE-ABS- KEY(internet) OR TITLE-ABS-KEY("Consumer Health Information")) AND (TITLE-ABS-KEY(consumer) OR TITLE-ABS-KEY("Patients") OR TITLE-ABS-KEY(caregivers)) AND (TITLE-ABS-KEY(access) OR TITLE- ABS-KEY(barrier) OR TITLE-ABS-KEY(facilitator) OR TITLE-ABS- KEY("user centered") OR TITLE-ABS-KEY("attitude to computers") OR TITLE-ABS-KEY(“computer literacy”) OR TITLE-ABS-KEY(“health knowledge, attitudes, practice”))) AND (LIMIT-TO(DOCTYPE, "ar") OR LIMIT-TO(DOCTYPE, "re") OR LIMIT-TO(DOCTYPE, "rp")) AND (LIMIT- TO(LANGUAGE, "English")) | | 5577
CINAHL | ((TX "Informatics" or TX telemedicine or TX internet or TX "Consumer Health Information" or TX “Support systems”) AND (TX consumer or TX "Patients" or TX parents or TX "age groups" or TX Caregivers) AND (TX "randomized controlled trial" or TX “controlled trial” or TX “clinical trial”) ) OR ((TX "Informatics" or TX telemedicine or TX internet or TX "Consumer Health Information" or TX “Support systems”) AND (TX consumer or TX "Patients" or TX parents or TX "age groups" or TX Caregivers) AND (TX Access or TX barrier or TX facilitator or TX compatibility or TX incompatibility or TX "user centered" or TX "work flow" or TX Reimbursement or TX Attitude or TX “computer literacy”) )NOT ((PT editorial )or (PT letter) or (PT comment)) | | 1462