# Appendix B Technical Experts and Peer Reviewers

- Patricia Flatley Brennan, RN, PhD
- Chair, Industrial & Systems Engineering College of Engineering
- Moehlman Bascom Professor School of Nursing University of Wisconsin-Madison
- 1513 University Avenue
- Madison, WI 53706

- Carol H. Cain, PhD
- Care Management Institute
- One Kaiser Plaza, 16th floor
- Oakland, CA 94612

- Sara Czaja, Ph.D.
- University of Miami Miller School of Medicine
- McArthur Engineering Building
- Miami, FL 33136

- Gunther Eysenbach, MD, MPH
- Centre for Global eHealth Innovation
- R. Fraser Elliott Building
- 190 Elizabeth Street
- Toronto, ON M5G 2C4

- Kenneth W. Goodman, Ph.D.
- University of Miami Ethics Programs
- P.O. Box 016960 (M-825)
- Miami, 33101

- Holly B. Jimison, PhD
- Oregon Health & Science University
- BICC
- Department of Medical Informatics & Clinical Epidemiology
- Portland, OR 97239

- Rita Kukafka, DrPH, MA
- Columbia University
- Department of Biomedical Informatics
- New York, NY 10032

- Musa Mayer
- 250 West 82 Street, #42
- New York, NY 10024

- Maryann Napoli
- Center for Medical Consumers
- 239 Thompson Street
- NY 10012-5030

- Eugene C. Rich MD FACP
- Scholar in Residence
- Association of American Medical Colleges
- 2450 N Street, NW
- Washington, DC 20037-1126

- Earl Steinberg, MD, MPP
- Resolution Health
- Columbia, MD 21044