# Appendix A List of Acronyms

Acronym | Definition
ADAS-Cog | Alzheimer’s disease assessment scale-cognitive
AHQ | Anxiety hierarchy questionnaire
AHRQ | Agency for Healthcare Research and Quality
AMIA | American medical informatics association
ANCOVA | Analysis of covariance
APHA | America public health association
ASMP | Arthritis self-management program
ASQ | Attributional style questionnaire
BAI | Beck Anxiety inventory
BDI | Beck Depression inventory
BMI | Body mass index
BtB | Beating the Blues
CBT | Cognitive behavioral theory
CESD | Center for Epidemiologic Studies-Depression
CES-D | Center for Epidemiologic Studies Depression
CgA | Chromogranin A
ChEIs | Cholinesterase inhibitors
CHESS | Comprehensive health enhancement support system
CHI | Consumer health informatics
CI | Confidence interval
CoNeg | Composite index for positive situations
CoPos | Composite index for negative situations
DHEA-S | Dehydroepiandosterone sulphate
DSMP | Dyspnea self-management programs
DXA | Dual-energy x-ray absorptiometry
EPC | Evidence-based Practice Center
EPSI | Exam problem-solving inventory
FFB | Kristal Fat and Fiber Behavior
HDS | Health distress scale
IEEE | Institute of Electrical and Electronics Engineers
IET | Industrial engineering technology
IMIS | Interactive multimedia internet-based system
IPP | Integrated psychostimulation program
ISI | International standards institute
IT | Information technology
MeSH | Medical subject heading
MMSE | Mini-mental state examination
NET | Internet-based CBT
NPY | Neuropeptide Y
PCS | Perceived competence scales
PDA | Personal digital assistant
PDF | Portable document format
RCT | Randomized controlled trial
SB2-BED | Student bodies 2-binge eating disorder
SD | Standard deviation
SDSCA | Summary of Diabetes Self Care Activities
TAI | Test anxiety inventory
TEP | Technical expert panel
TNFα | Tumor necrosis factor α
WHO | World Health organization
WSAS | Work and Social Adjustment Scale