# References and Included Studies

1 U. S. Census Bureau. (2008). Table 2. Annual Estimates of the Population by Sex and Selected Age Groups for the United States: April 1, 2000 to July 1, 2007 (NC-EST2007-02).
2 Lawrence JM, Lukacz ES, Nager CW, et al. (2008). Prevalence and co-occurrence of pelvic floor disorders in community-dwelling women. Obstet Gynecol.
3 Lukacz ES, Lawrence JM, Contreras R, et al. (2006). Parity, mode of delivery, and pelvic floor disorders. Obstet Gynecol.
4 Wagner TH, Hu TW, Bentkover J, et al. (2002). Health-related consequences of overactive bladder. Am J Manag Care.
5 Hozo SP, Djulbegovic B, Hozo I. (2005). Estimating the mean and variance from the median, range, and the size of a sample. BMC Med Res Methodol.
6 DerSimonian R, Laird N. (1986). Meta-analysis in clinical trials. Control Clin Trials.
7 Sismondo S. (2008). How pharmaceutical industry funding affects trial outcomes: causal structures and responses. Soc Sci Med.
8 Sismondo S. (2008). Pharmaceutical company funding and its consequences: a qualitative systematic review. Contemp Clin Trials.
9 Lexchin J, Bero LA, Djulbegovic B, et al. (2003). Pharmaceutical industry sponsorship and research outcome and quality: systematic review. BMJ.
10 Fenner DE, Trowbridge ER, Patel DL, et al. (2008). Establishing the prevalence of incontinence study: racial differences in women's patterns of urinary incontinence. J Urol.
11 Dooley Y, Kenton K, Cao G, et al. (2008). Urinary incontinence prevalence: results from the National Health and Nutrition Examination Survey. J Urol.
12 Herschorn S, Gajewski J, Schulz J, et al. (2008). A population-based study of urinary symptoms and incontinence: the Canadian Urinary Bladder Survey. BJU Int.
13 Lawrence JM, Lukacz ES, Liu IL, et al. (2007). Pelvic floor disorders, diabetes, and obesity in women: findings from the Kaiser Permanente Continence Associated Risk Epidemiology Study. Diabetes Care.
14 Choo MS, Ku JH, Lee JB, et al. (2007). Cross-cultural differences for adapting overactive bladder symptoms: results of an epidemiologic survey in Korea. World J Urol.
15 Townsend MK, Danforth KN, Lifford KL, et al. (2007). Incidence and remission of urinary incontinence in middle-aged women. Am J Obstet Gynecol.
16 Link CL, Lutfey KE, Steers WD, et al. (2007). Is abuse causally related to urologic symptoms? Results from the Boston Area Community Health (BACH) Survey. Eur Urol.
17 Waetjen LE, Liao S, Johnson WO, et al. (2007). Factors associated with prevalent and incident urinary incontinence in a cohort of midlife women: a longitudinal analysis of data: study of women's health across the nation. Am J Epidemiol.
18 Irwin DE, Milsom I, Hunskaar S, et al. (2006). Population-based survey of urinary incontinence, overactive bladder, and other lower urinary tract symptoms in five countries: results of the EPIC study. Eur Urol.
19 Huang AJ, Thom DH, Kanaya AM, et al. (2006). Urinary incontinence and pelvic floor dysfunction in Asian-American women. Am J Obstet Gynecol.
20 Hsieh CH, Chen HY, Hsu CS, et al. (2006). Prevalence of urinary frequency in Taiwanese women aged 20–59 years. Taiwan J Obstet Gynecol.
21 Homma Y, Yamaguchi O, Hayashi K. (2006). Epidemiologic survey of lower urinary tract symptoms in Japan. Urology.
22 Odeyemi IA, Dakin HA, O'Donnell RA, et al. (2006). Epidemiology, prescribing patterns and resource use associated with overactive bladder in UK primary care. Int J Clin Pract.
23 Teloken C, Caraver F, Weber FA, et al. (2006). Overactive bladder: prevalence and implications in Brazil. Eur Urol.
24 Kim SH, Boye M, Bhattacharyya SK, et al. (2006). Medical visits among adults with symptoms commonly associated with an overactive bladder. BJU Int.
25 Fitzgerald MP, Thom DH, Wassel-Fyr C, et al. (2006). Childhood urinary symptoms predict adult overactive bladder symptoms. J Urol.
26 McGrother CW, Donaldson MM, Hayward T, et al. (2006). Urinary storage symptoms and comorbidities: a prospective population cohort study in middle-aged and older women. Age Ageing.
27 Thom DH, van den Eeden SK, Ragins AI, et al. (2006). Differences in prevalence of urinary incontinence by race/ethnicity. J Urol.
28 Donaldson MM, Thompson JR, Matthews RJ, et al. (2006). The natural history of overactive bladder and stress urinary incontinence in older women in the community: a 3-year prospective cohort study. Neurourol Urodyn.
29 Zhang W, Song Y, He X, et al. (2006). Prevalence and risk factors of overactive bladder syndrome in Fuzhou Chinese women. Neurourol Urodyn.
30 Yu HJ, Liu CY, Lee KL, et al. (2006). Overactive bladder syndrome among community-dwelling adults in Taiwan: prevalence, correlates, perception, and treatment seeking. Urol Int.
31 Homma Y, Yamaguchi O, Hayashi K. (2005). An epidemiological survey of overactive bladder symptoms in Japan. BJU Int.
32 MacDiarmid S, Rosenberg M. (2005). Overactive bladder in women: symptom impact and treatment expectations. Curr Med Res Opin.
33 Zhang W, Song Y, He X, et al. (2005). Prevalence and risk factors of lower urinary tract symptoms in Fuzhou Chinese women. Eur Urol.
34 Song YF, Zhang WJ, Song J, et al. (2005). Prevalence and risk factors of urinary incontinence in Fuzhou Chinese women. Chin Med J (Engl).
35 Shakhatreh FM. (2005). Epidemiology of urinary incontinence in Jordanian women. Saudi Med J.
36 Muller N. (2005). What Americans understand and how they are affected by bladder control problems: highlights of recent nationwide consumer research. Urol Nurs.
37 Rohr G, Christensen K, Ulstrup K, et al. (2004). Reproducibility and validity of simple questions to identify urinary incontinence in elderly women. Acta Obstet Gynecol Scand.
38 Corcos J, Schick E. (2004). Prevalence of overactive bladder and incontinence in Canada. Can J Urol.
39 Dallosso HM, McGrother CW, Matthews RJ, et al. (2004). Nutrient composition of the diet and the development of overactive bladder: a longitudinal study in women. Neurourol Urodyn.
40 Espino DV, Palmer RF, Miles TP, et al. (2003). Prevalence and severity of urinary incontinence in elderly Mexican-American women. J Am Geriatr Soc.
41 Chen YC, Chen GD, Hu SW, et al. (2003). Is the occurrence of storage and voiding dysfunction affected by menopausal transition or associated with the normal aging process. Menopause.
42 Stewart WF, Van Rooyen JB, Cundiff GW, et al. (2003). Prevalence and burden of overactive bladder in the United States. World J Urol.
43 Siracusano S, Pregazzi R, d'Aloia G, et al. (2003). Prevalence of urinary incontinence in young and middle-aged women in an Italian urban area. Eur J Obstet Gynecol Reprod Biol.
44 Rortveit G, Daltveit AK, Hannestad YS, et al. (2003). Urinary incontinence after vaginal delivery or cesarean section. N Engl J Med.
45 Eva UF, Gun W, Preben K. (2003). Prevalence of urinary and fecal incontinence and symptoms of genital prolapse in women. Acta Obstet Gynecol Scand.
46 Yip SK, Chung TK. (2003). Treatment-seeking behavior in Hong Kong Chinese women with urinary symptoms. Int Urogynecol J Pelvic Floor Dysfunct.
47 Chen GD, Lin TL, Hu SW, et al. (2003). Prevalence and correlation of urinary incontinence and overactive bladder in Taiwanese women. Neurourol Urodyn.
48 van der Vaart CH, de Leeuw JR, Roovers JP, et al. (2002). The effect of urinary incontinence and overactive bladder symptoms on quality of life in young women. BJU Int.
49 Liu C, Andrews GR. (2002). Prevalence and incidence of urinary incontinence in the elderly: a longitudinal study in South Australia. Chin Med J (Engl).
50 Aaron R, Muliyil J, Abraham S. (2002). Medico-social dimensions of menopause: a cross-sectional study from rural south India. Natl Med J India.
51 Milsom I, Abrams P, Cardozo L, et al. (2001). How widespread are the symptoms of an overactive bladder and how are they managed? A population-based prevalence study. BJU Int.
52 Tseng IJ, Chen YT, Chen MT, et al. (2000). Prevalence of urinary incontinence and intention to seek treatment in the elderly. J Formos Med Assoc.
53 Moller LA, Lose G, Jorgensen T. (2000). The prevalence and bothersomeness of lower urinary tract symptoms in women 40–60 years of age. Acta Obstet Gynecol Scand.
54 Ueda T, Tamaki M, Kageyama S, et al. (2000). Urinary incontinence among community-dwelling people aged 40 years or older in Japan: prevalence, risk factors, knowledge and self-perception. Int J Urol.
55 Bortolotti A, Bernardini B, Colli E, et al. (2000). Prevalence and risk factors for urinary incontinence in Italy. Eur Urol.
56 Kuh D, Cardozo L, Hardy R. (1999). Urinary incontinence in middle aged women: childhood enuresis and other lifetime risk factors in a British prospective cohort. J Epidemiol Community Health.
57 Simeonova Z, Milsom I, Kullendorff AM, et al. (1999). The prevalence of urinary incontinence and its influence on the quality of life in women from an urban Swedish population. Acta Obstet Gynecol Scand.
58 Kay L, Stigsby B, Brasso K, et al. (1999). Lower urinary tract symptoms--a population survey using the Danish Prostatic Symptom Score (DAN-PSS) questionnaire. Scand J Urol Nephrol.
59 Koyama W, Koyanagi A, Mihara S, et al. (1998). Prevalence and conditions of urinary incontinence among the elderly. Methods Inf Med.
60 Schulman C, Claes H, Matthijs J. (1997). Urinary incontinence in Belgium: a population-based epidemiological survey. Eur Urol.
61 Brieger GM, Mongelli M, Hin LY, et al. (1997). The epidemiology of urinary dysfunction in Chinese women. Int Urogynecol J Pelvic Floor Dysfunct.
62 Bogren MA, Hvarfwen E, Fridlund B. (1997). Urinary incontinence among a 65-year old Swedish population: medical history and psychosocial consequences. Vard Nord Utveckl Forsk.
63 Brieger GM, Yip SK, Hin LY, et al. (1996). The prevalence of urinary dysfunction in Hong Kong Chinese women. Obstet Gynecol.
64 Nygaard IE, Lemke JH. (1996). Urinary incontinence in rural older women: prevalence, incidence and remission. J Am Geriatr Soc.
65 Lara C, Nacey J. (1994). Ethnic differences between Maori, Pacific Island and European New Zealand women in prevalence and attitudes to urinary incontinence. N Z Med J.
66 Ju CC, Swan LK, Merriman A, et al. (1991). Urinary incontinence among the elderly people of Singapore. Age Ageing.
67 Hording U, Pedersen KH, Sidenius K, et al. (1986). Urinary incontinence in 45-year-old women. An epidemiological survey. Scand J Urol Nephrol.
68 Iosif CS, Bekassy Z. (1984). Prevalence of genito-urinary symptoms in the late menopause. Acta Obstet Gynecol Scand.
69 Danforth KN, Shah AD, Townsend MK, et al. (2007). Physical activity and urinary incontinence among healthy, older women. Obstet Gynecol.
70 Ege E, Akin B, Altuntug K, et al. (2008). Prevalence of urinary incontinence in the 12-month postpartum period and related risk factors in Turkey. Urol Int.
71 Hall SA, Cinar A, Link CL, et al. (2008). Do urological symptoms cluster among women? Results from the Boston Area Community Health Survey. BJU Int.
72 Minassian VA, Stewart WF, Wood GC. (2008). Urinary incontinence in women: variation in prevalence estimates and risk factors. Obstet Gynecol.
73 Tikkinen KA, Auvinen A, Tiitinen A, et al. (2008). Reproductive factors associated with nocturia and urinary urgency in women: a population-based study in Finland. Am J Obstet Gynecol.
74 Townsend MK, Curhan GC, Resnick NM, et al. (2008). BMI, waist circumference, and incident urinary incontinence in older women. Obesity (Silver Spring).
75 Wesnes SL, Rortveit G, Bo K, et al. (2007). Urinary incontinence during pregnancy. Obstet Gynecol.
76 Hannestad YS, Rortveit G, Sandvik H, et al. (2000). A community-based epidemiological survey of female urinary incontinence: the Norwegian EPINCONT study. Epidemiology of Incontinence in the County of Nord-Trondelag. J Clin Epidemiol.
77 Herzog AR, Diokno AC, Brown MB, et al. (1990). Two-year incidence, remission, and change patterns of urinary incontinence in noninstitutionalized older adults. J Gerontol.
78 Perry S, Shaw C, Assassa P, et al. (2000). An epidemiological study to establish the prevalence of urinary symptoms and felt need in the community: the Leicestershire MRC Incontinence Study. Leicestershire MRC Incontinence Study Team. J Public Health Med.
79 Yarnell JW, Voyle GJ, Richards CJ, et al. (1981). The prevalence and severity of urinary incontinence in women. J Epidemiol Community Health.
80 Zhu L, Lang J, Wang H, et al. (2008). The prevalence of and potential risk factors for female urinary incontinence in Beijing, China. Menopause.
81 Nuotio M, Tammela TL, Luukkaala T, et al. (2002). Urgency and urge incontinence in an older population: ten-year changes and their association with mortality. Aging Clin Exp Res.
82 Zinner N, Tuttle J, Marks L. (2005). Efficacy and tolerability of darifenacin, a muscarinic M3 selective receptor antagonist (M3 SRA), compared with oxybutynin in the treatment of patients with overactive bladder. World J Urol.
83 Sand PK, Miklos J, Ritter H, et al. (2004). A comparison of extended-release oxybutynin and tolterodine for treatment of overactive bladder in women. Int Urogynecol J Pelvic Floor Dysfunct.
84 Diokno AC, Appell RA, Sand PK, et al. (2003). Prospective, randomized, double-blind study of the efficacy and tolerability of the extended-release formulations of oxybutynin and tolterodine for overactive bladder: results of the OPERA trial. Mayo Clin Proc.
85 Dmochowski RR, Davila GW, Zinner NR, et al. (2002). Efficacy and safety of transdermal oxybutynin in patients with urge and mixed urinary incontinence. J Urol.
86 Sussman D, Garely A. (2002). Treatment of overactive bladder with once-daily extended-release tolterodine or oxybutynin: the antimuscarinic clinical effectiveness trial (ACET). Curr Med Res Opin.
87 Davila GW, Daugherty CA, Sanders SW. (2001). A short-term, multicenter, randomized double-blind dose titration study of the efficacy and anticholinergic side effects of transdermal compared to immediate release oral oxybutynin treatment of patients with urge urinary incontinence. J Urol.
88 Dmochowski RR, Sand PK, Zinner NR, et al. (2003). Comparative efficacy and safety of transdermal oxybutynin and oral tolterodine versus placebo in previously treated patients with urge and mixed urinary incontinence. Urology.
89 Giannitsas K, Perimenis P, Athanasopoulos A, et al. (2004). Comparison of the efficacy of tolterodine and oxybutynin in different urodynamic severity grades of idiopathic detrusor overactivity. Eur Urol.
90 Halaska M, Ralph G, Wiedemann A, et al. (2003). Controlled, double-blind, multicentre clinical trial to investigate long-term tolerability and efficacy of trospium chloride in patients with detrusor instability. World J Urol.
91 Abrams P, Freeman R, Anderstrom C, et al. (1998). Tolterodine, a new antimuscarinic agent: as effective but better tolerated than oxybutynin in patients with an overactive bladder. Br J Urol.
92 Homma Y, Koyama N. (2006). Minimal clinically important change in urinary incontinence detected by a quality of life assessment tool in overactive bladder syndrome with urge incontinence. Neurourol Urodyn.
93 Wang AC, Chih SY, Chen MC. (2006). Comparison of electric stimulation and oxybutynin chloride in management of overactive bladder with special reference to urinary urgency: a randomized placebo-controlled trial. Urology.
94 Lee JG, Hong JY, Choo MS, et al. (2002). Tolterodine: as effective but better tolerated than oxybutynin in Asian patients with symptoms of overactive bladder. Int J Urol.
95 Nitti VW, Dmochowski R, Sand PK, et al. (2007). Efficacy, safety and tolerability of fesoterodine for overactive bladder syndrome. J Urol.
96 Chapple C, Van Kerrebroeck P, Tubaro A, et al. (2007). Clinical efficacy, safety, and tolerability of once-daily fesoterodine in subjects with overactive bladder. Eur Urol.
97 Chapple CR, Rechberger T, Al-Shukri S, et al. (2004). Randomized, double-blind placebo- and tolterodine-controlled trial of the once-daily antimuscarinic agent solifenacin in patients with symptomatic overactive bladder. BJU Int.
98 Yamaguchi O, Marui E, Kakizaki H, et al. (2007). Randomized, double-blind, placebo- and propiverine-controlled trial of the once-daily antimuscarinic agent solifenacin in Japanese patients with overactive bladder. BJU Int.
99 Chapple CR, Fianu-Jonsson A, Indig M, et al. (2007). Treatment outcomes in the STAR study: a subanalysis of solifenacin 5 mg and tolterodine ER 4 mg. Eur Urol.
100 Hill S, Khullar V, Wyndaele JJ, et al. (2006). Dose response with darifenacin, a novel once-daily M3 selective receptor antagonist for the treatment of overactive bladder: results of a fixed dose study. Int Urogynecol J Pelvic Floor Dysfunct.
101 Zinner N, Susset J, Gittelman M, et al. (2006). Efficacy, tolerability and safety of darifenacin, an M(3) selective receptor antagonist: an investigation of warning time in patients with OAB. Int J Clin Pract.
102 Steers W, Corcos J, Foote J, et al. (2005). An investigation of dose titration with darifenacin, an M3-selective receptor antagonist. BJU Int.
103 Staskin D, Sand P, Zinner N, et al. (2007). daily trospium chloride is effective and well tolerated for the treatment of overactive bladder: results from a multicenter phase III trial. J Urol.
104 Rudy D, Cline K, Harris R, et al. (2006). Time to onset of improvement in symptoms of overactive bladder using antimuscarinic treatment. BJU Int.
105 Dmochowski RR, Sand PK, Zinner NR, et al. (2008). Trospium 60 mg once daily (QD) for overactive bladder syndrome: results from a placebo-controlled interventional study. Urology.
106 Zinner N, Gittelman M, Harris R, et al. (2004). Trospium chloride improves overactive bladder symptoms: a multicenter phase III trial. J Urol.
107 Cardozo L, Rekers H, Tapp A, et al. (1993). Oestriol in the treatment of postmenopausal urgency: a multicentre study. Maturitas.
108 Lose G, Englev E. (2000). Oestradiol-releasing vaginal ring versus oestriol vaginal pessaries in the treatment of bothersome lower urinary tract symptoms. BJOG.
109 Molander U, Milsom I, Ekelund P, et al. (1991). A health care program for the investigation and treatment of elderly women with urinary incontinence and related urogenital symptoms. Acta Obstet Gynecol Scand.
110 Groenendijk PM, Lycklama a Nyeholt AA, Heesakkers JP, et al. (2008). Urodynamic evaluation of sacral neuromodulation for urge urinary incontinence. BJU Int.
111 Janknegt RA, Hassouna MM, Siegel SW, et al. (2001). Long-term effectiveness of sacral nerve stimulation for refractory urge incontinence. Eur Urol.
112 Kessler TM, Buchser E, Meyer S, et al. (2007). Sacral neuromodulation for refractory lower urinary tract dysfunction: results of a nationwide registry in Switzerland. Eur Urol.
113 Koldewijn EL, Rosier PF, Meuleman EJ, et al. (1994). Predictors of success with neuromodulation in lower urinary tract dysfunction: results of trial stimulation in 100 patients. J Urol.
114 Siegel SW, Catanzaro F, Dijkema HE, et al. (2000). Long-term results of a multicenter study on sacral nerve stimulation for treatment of urinary urge incontinence, urgency-frequency, and retention. Urology.
115 van Kerrebroeck PE, van Voskuilen AC, Heesakkers JP, et al. (2007). Results of sacral neuromodulation therapy for urinary voiding dysfunction: outcomes of a prospective, worldwide clinical study. J Urol.
116 Fossberg E, Sorensen S, Ruutu M, et al. (1990). Maximal electrical stimulation in the treatment of unstable detrusor and urge incontinence. Eur Urol.
117 Schmid DM, Sauermann P, Werner M, et al. (2006). Experience with 100 cases treated with botulinum-A toxin injections in the detrusor muscle for idiopathic overactive bladder syndrome refractory to anticholinergics. J Urol.
118 Korda A, Krieger M, Hunter P. (1987). The use of prolonged bladder distension in the treatment of intractable urinary incontinence in females with detrusor instability. Aust N Z J Obstet Gynaecol.
119 Sutherland SE, Lavers A, Carlson A, et al. (2007). Sacral nerve stimulation for voiding dysfunction: One institution's 11-year experience. Neurourol Urodyn.
120 van Voskuilen AC, Oerlemans DJ, Weil EH, et al. (2006). Long term results of neuromodulation by sacral nerve stimulation for lower urinary tract symptoms: a retrospective single center study. Eur Urol.
121 Mundy AR. (1983). Long-term results of bladder transection for urge incontinence. Br J Urol.
122 Spinelli M, Bertapelle P, Cappellano F, et al. (2001). Chronic sacral neuromodulation in patients with lower urinary tract symptoms: results from a national register. J Urol.
123 Hassouna MM, Siegel SW, Nyeholt AA, et al. (2000). Sacral neuromodulation in the treatment of urgency-frequency symptoms: a multicenter study on efficacy and safety. J Urol.
124 Schmidt RA, Jonas U, Oleson KA, et al. (1999). Sacral nerve stimulation for treatment of refractory urinary urge incontinence. Sacral Nerve Stimulation Study Group. J Urol.
125 O'Reilly BA, Fynes M, Achtari C, et al. (2008). A prospective randomised double-blind controlled trial evaluating the effect of trans-sacral magnetic stimulation in women with overactive bladder. Int Urogynecol J Pelvic Floor Dysfunct.
126 Enzelsberger H, Helmer H, Kurz C. (1995). Intravesical instillation of oxybutynin in women with idiopathic detrusor instability: a randomised trial. Br J Obstet Gynaecol.
127 Rios LA, Panhoca R, Mattos D, et al. (2007). Intravesical resiniferatoxin for the treatment of women with idiopathic detrusor overactivity and urgency incontinence: A single dose, 4 weeks, double-blind, randomized, placebo controlled trial. Neurourol Urodyn.
128 Duthie J, Wilson DI, Herbison GP, et al. (2007). Botulinum toxin injections for adults with overactive bladder syndrome. Cochrane Database of Systematic Reviews.
129 Frewen WK. (1982). A reassessment of bladder training in detrusor dysfunction in the female. Br J Urol.
130 Dorey G, Sultan H, Eckford SD, et al. (2006). Pelvic floor muscle exercises and urge suppression techniques in women with urge urinary incontinence: a retrospective study from a dedicated urogynaecology clinic. Journal of the Association of Chartered Physiotherapists in Women's Health.
131 Millard RJ, Oldenburg BF. (1983). The symptomatic, urodynamic and psychodynamic results of bladder reeducation programs. J Urol.
132 Dowd T, Kolcaba K, Steiner R. (2003). The addition of coaching to cognitive strategies: interventions for persons with compromised urinary bladder syndrome. J Wound Ostomy Continence Nurs.
133 Jarvis GJ, Millar DR. (1980). Controlled trial of bladder drill for detrusor instability. Br Med J.
134 Wyman JF, Fantl JA, McClish DK, et al. (1998). Comparative efficacy of behavioral interventions in the management of female urinary incontinence. Continence Program for Women Research Group. Am J Obstet Gynecol.
135 Burgio KL, Goode PS, Locher JL, et al. (2002). Behavioral training with and without biofeedback in the treatment of urge incontinence in older women: a randomized controlled trial. JAMA.
136 Bryant CM, Dowell CJ, Fairbrother G. (2002). Caffeine reduction education to improve urinary symptoms. Br J Nurs.
137 Emmons SL, Otto L. (2005). Acupuncture for overactive bladder: a randomized controlled trial. Obstet Gynecol.
138 Mak HL, Cheon WC, Wong T, et al. (2007). Randomized controlled trial of foot reflexology for patients with symptomatic idiopathic detrusor overactivity. Int Urogynecol J Pelvic Floor Dysfunct.
139 Freeman RM, Baxby K. (1982). Hypnotherapy for incontinence caused by the unstable detrusor. Br Med J (Clin Res Ed).
140 Swift S, Garely A, Dimpfl T, et al. (2003). A new once-daily formulation of tolterodine provides superior efficacy and is well tolerated in women with overactive bladder. Int Urogynecol J Pelvic Floor Dysfunct.
141 Van Kerrebroeck P, Kreder K, Jonas U, et al. (2001). Tolterodine once-daily: superior efficacy and tolerability in the treatment of the overactive bladder. Urology.
142 Chapple CR, Van Kerrebroeck PE, Junemann KP, et al. (2008). Comparison of fesoterodine and tolterodine in patients with overactive bladder. BJU Int.
143 Burgio KL, Locher JL, Goode PS, et al. (1998). Behavioral vs drug treatment for urge urinary incontinence in older women: a randomized controlled trial. JAMA.
144 Burgio KL, Locher JL, Roth DL, et al. (2001). Psychological improvements associated with behavioral and drug treatment of urge incontinence in older women. J Gerontol B Psychol Sci Soc Sci.
145 Goode PS, Burgio KL, Locher JL, et al. (2002). Urodynamic changes associated with behavioral and drug treatment of urge incontinence in older women. J Am Geriatr Soc.
146 Colombo M, Zanetta G, Scalambrino S, et al. (1995). Oxybutynin and bladder training in the management of female urge urinary incontinence: a randomized study. Int Urogynecol J.
147 Diokno A, Yuhico M. (1995). Preference, compliance and initial outcome of therapeutic options chosen by female patients with urinary incontinence. J Urol.
148 Macaulay AJ, Stern RS, Holmes DM, et al. (1987). Micturition and the mind: psychological factors in the aetiology and treatment of urinary symptoms in women. Br Med J (Clin Res Ed).
149 Jarvis GJ. (1981). A controlled trial of bladder drill and drug therapy in the management of detrusor instability. Br J Urol.
150 Song C, Park JT, Heo KO, et al. (2006). Effects of bladder training and/or tolterodine in female patients with overactive bladder syndrome: a prospective, randomized study. J Korean Med Sci.
151 Mattiasson A, Blaakaer J, Hoye K, et al. (2003). Simplified bladder training augments the effectiveness of tolterodine in patients with an overactive bladder. BJU Int.
152 Burgio KL, Kraus SR, Menefee S, et al. (2008). Behavioral therapy to enable women with urge incontinence to discontinue drug treatment: a randomized trial. Ann Intern Med.
153 Chancellor MB, Kianifard F, Beamer E, et al. (2008). A comparison of the efficacy of darifenacin alone vs. darifenacin plus a Behavioural Modification Programme upon the symptoms of overactive bladder. Int J Clin Pract.
154 Millard RJ. (2004). Clinical efficacy of tolterodine with or without a simplified pelvic floor exercise regimen. Neurourol Urodyn.
155 Herschorn S, Becker D, Miller E, et al. (2004). Impact of a health education intervention in overactive bladder patients. Can J Urol.
156 Layton D, Pearce GL, Shakir SA. (2001). Safety profile of tolterodine as used in general practice in England: results of prescription-event monitoring. Drug Saf.
157 Michel MC, Schneider T, Krege S, et al. (2002). Does gender or age affect the efficacy and safety of tolterodine?. J Urol.
158 Zinner NR, Mattiasson A, Stanton SL. (2002). Efficacy, safety, and tolerability of extended-release once-daily tolterodine treatment for overactive bladder in older versus younger patients. J Am Geriatr Soc.
159 Hill S, Elhilali M, Millard RJ, et al. (2007). Long-term darifenacin treatment for overactive bladder in patients aged 65 years and older: analysis of results from a 2-year, open-label extension study. Curr Med Res Opin.
160 Elinoff V, Bavendam T, Glasser DB, et al. (2006). Symptom-specific efficacy of tolterodine extended release in patients with overactive bladder: the IMPACT trial. Int J Clin Pract.
161 Staskin DR, Harnett MD. (2004). Effect of trospium chloride on somnolence and sleepiness in patients with overactive bladder. Curr Urol Rep.
162 Jacquetin B, Wyndaele J. (2001). Tolterodine reduces the number of urge incontinence episodes in patients with an overactive bladder. Eur J Obstet Gynecol Reprod Biol.
163 Appell RA, Abrams P, Drutz HP, et al. (2001). Treatment of overactive bladder: long-term tolerability and efficacy of tolterodine. World J Urol.
164 Anderson RU, MacDiarmid S, Kell S, et al. (2006). Effectiveness and tolerability of extended-release oxybutynin vs extended-release tolterodine in women with or without prior anticholinergic treatment for overactive bladder. Int Urogynecol J Pelvic Floor Dysfunct.
165 Gleason DM, Susset J, White C, et al. (1999). Evaluation of a new once-daily formulation of oxbutynin for the treatment of urinary urge incontinence. Ditropan XL Study Group. Urology.
166 Michel MC, de la Rosette JJ, Piro M, et al. (2005). Comparison of symptom severity and treatment response in patients with incontinent and continent overactive bladder. Eur Urol.
167 Garely AD, Lucente V, Vapnek J, et al. (2007). Solifenacin for overactive bladder with incontinence: symptom bother and health-related quality of life outcomes. Ann Pharmacother.
168 Landis JR, Kaplan S, Swift S, et al. (2004). Efficacy of antimuscarinic therapy for overactive bladder with varying degrees of incontinence severity. J Urol.
169 Kreder KJ, Brubaker L, Mainprize T. (2003). Tolterodine is equally effective in patients with mixed incontinence and those with urge incontinence alone. BJU Int.
170 Steers WD, Herschorn S, Kreder KJ, et al. (2007). Duloxetine compared with placebo for treating women with symptoms of overactive bladder. BJU Int.
171 Malone-Lee J, Henshaw DJ, Cummings K. (2003). Urodynamic verification of an overactive bladder is not a prerequisite for antimuscarinic treatment response. BJU Int.
172 Salvatore S, Serati M, Digesu GA, et al. (2008). Efficacy of tolterodine in relation to different urodynamic findings of detrusor overactivity. Int Urogynecol J Pelvic Floor Dysfunct.
173 Serati M, Salvatore S, Uccella S, et al. (2008). Urinary incontinence at orgasm: relation to detrusor overactivity and treatment efficacy. Eur Urol.
174 Freeman R, Hill S, Millard R, et al. (2003). Reduced perception of urgency in treatment of overactive bladder with extended-release tolterodine. Obstet Gynecol.
175 Varadharajan S, Jumadilova Z, Girase P, et al. (2005). Economic impact of extended-release tolterodine versus immediate- and extended-release oxybutynin among commercially insured persons with overactive bladder. Am J Manag Care.
176 Hall JA, Nelson MA, Meyer JW, et al. (2001). Costs and resources associated with the treatment of overactive bladder using retrospective medical care claims data. Manag Care Interface.
177 Jensen GA, Zhou Z, Torigoe Y. (2003). Medical care of overactive bladder in elderly patients. Journal of Aging & Pharmacotherapy.
178 Nitz NM, Jumadilova Z, Darkow T, et al. (2005). Medical costs after initiation of drug treatment for overactive bladder: effects of selection bias on cost estimates. Am J Manag Care.
179 Hu TW, Wagner TH, Bentkover JD, et al. (2003). Estimated economic costs of overactive bladder in the United States. Urology.
180 Abrams P, Cardozo L, Fall M, et al. (2002). The standardisation of terminology of lower urinary tract function: report from the Standardisation Sub-committee of the International Continence Society. Neurourol Urodyn.
181 Gardyn R. (1999). Detrol. Advertising Age.
182 Fisher JA. (2009). Medical Research for Hire: The Political Economy of Pharmaceutical Clinical Trials.
183 Kassirer JP. (2005). On the Take: How America's Complicity with Big Business Can Endanger Your Health.
184 Ronald L. (2006). Empowered to Consume: Direct-to-consumer advertising and pharmaceutical governance.
185 Petersen M. (2008). Our Daily Meds: How the Pharmaceutical Companies Transformed Themselves into Slick Marketing Machines and Hooked the Nation on Prescription Drugs.
186 Pfizer. (2007). Pfizer Achieves Key 2006 Financial Targetes.
187 Bren L. (2005). Controlling Urinary Incontinence. FDA Consumer Magazine.
188 Brown JS, Vittinghoff E, Wyman JF, et al. (2000). Urinary incontinence: does it increase risk for falls and fractures? Study of Osteoporotic Fractures Research Group. J Am Geriatr Soc.
189 Darkow T, Fontes CL, Williamson TE. (2005). Costs associated with the management of overactive bladder and related comorbidities. Pharmacotherapy.
190 Matchar DB, Myers ER, Barber MW, et al. (2001). Management of uterine fibroids. Evid Rep Technol Assess (Summ).
191 Schulz KF, Chalmers I, Grimes DA, et al. (1994). Assessing the quality of randomization from reports of controlled trials published in obstetrics and gynecology journals. JAMA.
192 Schulz KF, Chalmers I, Hayes RJ, et al. (1995). Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA.
193 Altman DG, Schulz KF, Moher D, et al. (2001). The revised CONSORT statement for reporting randomized trials: explanation and elaboration. Ann Intern Med.
194 West S, King V, Carey TS, et al. (2002). Systems to rate the strength of scientific evidence. Evid Rep Technol Assess (Summ).
195 Viswanathan M, Hartmann K, McKoy N, et al. (2007). Management of Uterine Fibroids: An Update of the Evidence. Evidence Report/Technology Assessment No. 154 (Prepared by RTI International-University of North Carolina Evidence-based Practice Center under Contract No. 290-02-0016. AHRQ Publication No. 07–E011.
196 Shamliyan T, Wyman J, Bliss DZ, et al. (2007). Prevention of urinary and fecal incontinence in adults. Evid Rep Technol Assess (Full Rep).
197 Wilkinson E. (2006). Urinary incontinence in women. Nurs Times.
198 Abrams P, Cardozo L, Chapple C, et al. (2006). Comparison of the efficacy, safety, and tolerability of propiverine and oxybutynin for the treatment of overactive bladder syndrome. Int J Urol.
199 Anderson RU, Mobley D, Blank B, et al. (1999). Once daily controlled versus immediate release oxybutynin chloride for urge urinary incontinence. OROS Oxybutynin Study Group. J Urol.
200 Appell RA, Sand P, Dmochowski R, et al. (2001). Prospective randomized controlled trial of extended-release oxybutynin chloride and tolterodine tartrate in the treatment of overactive bladder: results of the OBJECT Study. Mayo Clin Proc.
201 Arruda RM, Castro RA, Sousa GC, et al. (2008). Prospective randomized comparison of oxybutynin, functional electrostimulation, and pelvic floor training for treatment of detrusor overactivity in women. Int Urogynecol J Pelvic Floor Dysfunct.
202 Barkin J, Corcos J, Radomski S, et al. (2004). A randomized, double-blind, parallel-group comparison of controlled- and immediate-release oxybutynin chloride in urge urinary incontinence. Clin Ther.
203 Bemelmans BL, Kiemeney LA, Debruyne FM. (2000). Low-dose oxybutynin for the treatment of urge incontinence: good efficacy and few side effects. Eur Urol.
204 Boone TB, Kusek JW, Nyberg LM, et al. (2002). Treatment patterns and associated symptom improvement during six months of care for overactive bladder: a prospective, observational study. Clin Ther.
205 Capo JP, Laramee C, Lucente V, et al. (2008). Solifenacin treatment for overactive bladder in Hispanic patients: patient-reported symptom bother and quality of life outcomes from the VESIcare Open-Label Trial. Int J Clin Pract.
206 Cardozo L, Hessdorfer E, Milani R, et al. (2008). Solifenacin in the treatment of urgency and other symptoms of overactive bladder: results from a randomized, double-blind, placebo-controlled, rising-dose trial. BJU Int.
207 Cardozo L, Lisec M, Millard R, et al. (2004). Randomized, double-blind placebo controlled trial of the once daily antimuscarinic agent solifenacin succinate in patients with overactive bladder. J Urol.
208 Chancellor MB, Zinner N, Whitmore K, et al. (2008). Efficacy of solifenacin in patients previously treated with tolterodine extended release 4 mg: results of a 12-week, multicenter, open-label, flexible-dose study. Clin Ther.
209 Chancellor M, Freedman S, Mitcheson HD, et al. (2000). Tolterodine, an effective and well tolerated treatment for urge incontinence and other overactive bladder symptoms. Clinical Drug Investigation.
210 Chapple C, DuBeau C, Ebinger U, et al. (2007). Darifenacin treatment of patients >or= 65 years with overactive bladder: results of a randomized, controlled, 12-week trial. Curr Med Res Opin.
211 Chapple CR, Martinez-Garcia R, Selvaggi L, et al. (2005). A comparison of the efficacy and tolerability of solifenacin succinate and extended release tolterodine at treating overactive bladder syndrome: results of the STAR trial. Eur Urol.
212 Choo MS, Doo CK, Lee KS. (2008). Satisfaction with tolterodine: assessing symptom-specific patient-reported goal achievement in the treatment of overactive bladder in female patients (STARGATE study). Int J Clin Pract.
213 Chu FM, Dmochowski RR, Lama DJ, et al. (2005). Extended-release formulations of oxybutynin and tolterodine exhibit similar central nervous system tolerability profiles: a subanalysis of data from the OPERA trial. Am J Obstet Gynecol.
214 Diokno A, Sand P, Labasky R, et al. (2002). Long-term safety of extended-release oxybutynin chloride in a community-dwelling population of participants with overactive bladder: a one-year study. Int Urol Nephrol.
215 Dmochowski R, Kreder K, MacDiarmid S, et al. (2007). The clinical efficacy of tolterodine extended-release is maintained for 24 h in patients with overactive bladder. BJU Int.
216 Drutz HP, Appell RA, Gleason D, et al. (1999). Clinical efficacy and safety of tolterodine compared to oxybutynin and placebo in patients with overactive bladder. Int Urogynecol J Pelvic Floor Dysfunct.
217 Dwyer P, Kelleher C, Young J, et al. (2008). Long-term benefits of darifenacin treatment for patient quality of life: results from a 2-year extension study. Neurourol Urodyn.
218 Garely AD, Kaufman JM, Sand PK, et al. (2006). Symptom bother and health-related quality of life outcomes following solifenacin treatment for overactive bladder: the VESIcare Open-Label Trial (VOLT). Clin Ther.
219 Haab F, Corcos J, Siami P, et al. (2006). Long-term treatment with darifenacin for overactive bladder: results of a 2-year, open-label extension study. BJU Int.
220 Haab F, Cardozo L, Chapple C, et al. (2005). Long-term open-label solifenacin treatment associated with persistence with therapy in patients with overactive bladder syndrome. Eur Urol.
221 Jonas U, Hofner K, Madersbacher H, et al. (1997). Efficacy and safety of two doses of tolterodine versus placebo in patients with detrusor overactivity and symptoms of frequency, urge incontinence, and urgency: urodynamic evaluation. The International Study Group. World J Urol.
222 Karram MM, Toglia MR, Serels SR, et al. (2009). Treatment with solifenacin increases warning time and improves symptoms of overactive bladder: results from VENUS, a randomized, double-blind, placebo-controlled trial. Urology.
223 Kelleher CJ, Kreder KJ, Pleil AM, et al. (2002). Long-term health-related quality of life of patients receiving extended-release tolterodine for overactive bladder. Am J Manag Care.
224 Kelleher CJ, Reese PR, Pleil AM, et al. (2002). Health-related quality of life of patients receiving extended-release tolterodine for overactive bladder. Am J Manag Care.
225 Kelleher CJ, Cardozo L, Chapple CR, et al. (2005). Improved quality of life in patients with overactive bladder symptoms treated with solifenacin. BJU Int.
226 Koonings PP, Bergman A. (1991). Urethral pressure changes in women with detrusor instability. Bladder or urethral pathologic process?. Urology.
227 Kreder K, Mayne C, Jonas U. (2002). Long-term safety, tolerability and efficacy of extended-release tolterodine in the treatment of overactive bladder. Eur Urol.
228 Leung HY, Yip SK, Cheon C, et al. (2002). A randomized controlled trial of tolterodine and oxybutynin on tolerability and clinical efficacy for treating Chinese women with an overactive bladder. BJU Int.
229 Mallett V, Burks D, Garely AD, et al. (2007). Solifenacin treatment for overactive bladder in black patients: patient-reported symptom bother and health-related quality of life outcomes. Curr Med Res Opin.
230 Messelink EJ. (1999). Treatment of the overactive bladder with tolterodine, a new muscarinic receptor antagonist. BJU Int.
231 Michel MC, Wetterauer U, Vogel M, et al. (2008). Cardiovascular safety and overall tolerability of solifenacin in routine clinical use: a 12-week, open-label, post-marketing surveillance study. Drug Saf.
232 Michel MC, Oelke M, Goepel M, et al. (2007). Relationships among symptoms, bother, and treatment satisfaction in overactive bladder patients. Neurourol Urodyn.
233 Millard R, Tuttle J, Moore K, et al. (1999). Clinical efficacy and safety of tolterodine compared to placebo in detrusor overactivity. J Urol.
234 Minassian VA, Ross S, Sumabat O, et al. (2007). Randomized trial of oxybutynin extended versus immediate release for women aged 65 and older with overactive bladder: lessons learned from conducting a trial. J Obstet Gynaecol Can.
235 Moore KH, Sutherst JR. (1990). Response to treatment of detrusor instability in relation to psychoneurotic status. Br J Urol.
236 Moore KH, Hay DM, Imrie AE, et al. (1990). Oxybutynin hydrochloride (3 mg) in the treatment of women with idiopathic detrusor instability. Br J Urol.
237 Preik M, Albrecht D, O'Connell M, et al. (2004). Effect of controlled-release delivery on the pharmacokinetics of oxybutynin at different dosages: severity-dependent treatment of the overactive bladder. BJU Int.
238 Rentzhog L, Stanton SL, Cardozo L, et al. (1998). Efficacy and safety of tolterodine in patients with detrusor instability: a dose-ranging study. Br J Urol.
239 Roberts R, Bavendam T, Glasser DB, et al. (2006). Tolterodine extended release improves patient-reported outcomes in overactive bladder: results from the IMPACT trial. Int J Clin Pract.
240 Robinson D, Cardozo L, Terpstra G, et al. (2007). A randomized double-blind placebo-controlled multicentre study to explore the efficacy and safety of tamsulosin and tolterodine in women with overactive bladder syndrome. BJU Int.
241 Rogers R, Bachmann G, Jumadilova Z, et al. (2008). Efficacy of tolterodine on overactive bladder symptoms and sexual and emotional quality of life in sexually active women. Int Urogynecol J Pelvic Floor Dysfunct.
242 Rudy D, Cline K, Harris R, et al. (2006). Multicenter phase III trial studying trospium chloride in patients with overactive bladder. Urology.
243 Salvatore S, Serati M, Ghezzi F, et al. (2007). Efficacy of tolterodine in women with detrusor overactivity and anterior vaginal wall prolapse: is it the same?. BJOG.
244 Salvatore S, Khullar V, Cardozo L, et al. (2005). Long-term prospective randomized study comparing two different regimens of oxybutynin as a treatment for detrusor overactivity. Eur J Obstet Gynecol Reprod Biol.
245 Sand P, Zinner N, Newman D, et al. (2007). Oxybutynin transdermal system improves the quality of life in adults with overactive bladder: a multicentre, community-based, randomized study. BJU Int.
246 Sand PK, Goldberg RP, Dmochowski RR, et al. (2006). The impact of the overactive bladder syndrome on sexual function: a preliminary report from the Multicenter Assessment of Transdermal Therapy in Overactive Bladder with Oxybutynin trial. Am J Obstet Gynecol.
247 Tseng LH, Wang AC, Chang YL, et al. (2009). Randomized comparison of tolterodine with vaginal estrogen cream versus tolterodine alone for the treatment of postmenopausal women with overactive bladder syndrome. Neurourol Urodyn.
248 Versi E, Appell R, Mobley D, et al. (2000). Dry mouth with conventional and controlled-release oxybutynin in urinary incontinence. The Ditropan XL Study Group. Obstet Gynecol.
249 Wang PS, Levin R, Zhao SZ, et al. (2002). Urinary antispasmodic use and the risks of ventricular arrhythmia and sudden death in older patients. J Am Geriatr Soc.
250 Zinner N, Noe L, Rasouliyan L, et al. (2008). Impact of solifenacin on resource utilization, work productivity and health utility in overactive bladder patients switching from tolterodine ER. Curr Med Res Opin.
251 Burgio KL, Locher JL, Goode PS. (2000). Combined behavioral and drug therapy for urge incontinence in older women. J Am Geriatr Soc.
252 Fantl JA, Hurt WG, Dunn LJ. (1981). Detrusor instability syndrome: the use of bladder retraining drills with and without anticholinergics. Am J Obstet Gynecol.
253 Ghei M, Miller R, Malone-Lee J. (2006). Case series data to encourage randomized trials of bladder retraining compared to antimuscarinic agents. J Urol.
254 Lauti M, Herbison P, Hay-Smith J, et al. (2008). Anticholinergic drugs, bladder retraining and their combination for urge urinary incontinence: a pilot randomised trial. Int Urogynecol J Pelvic Floor Dysfunct.
255 Szonyi G, Collas DM, Ding YY, et al. (1995). Oxybutynin with bladder retraining for detrusor instability in elderly people: a randomized controlled trial. Age Ageing.
256 Oerlemans DJ, van Kerrebroeck PE. (2008). Sacral nerve stimulation for neuromodulation of the lower urinary tract. Neurourol Urodyn.
257 Cooperberg MR, Stoller ML. (2005). Percutaneous neuromodulation. Urol Clin North Am.
258 van Balken MR, Vandoninck V, Gisolf KW, et al. (2001). Posterior tibial nerve stimulation as neuromodulative treatment of lower urinary tract dysfunction. J Urol.
259 Vandoninck V, Van Balken MR, Finazzi Agro E, et al. (2003). Posterior tibial nerve stimulation in the treatment of urge incontinence. Neurourol Urodyn.
260 McGuire EJ, Zhang SC, Horwinski ER, et al. (1983). Treatment of motor and sensory detrusor instability by electrical stimulation. J Urol.
261 Goldberg RP, Sand PK. (2000). Electromagnetic pelvic floor stimulation: applications for the gynecologist. Obstet Gynecol Surv.
262 Giannantoni A, Di Stasi SM, Stephen RL, et al. (2004). Intravesical resiniferatoxin versus botulinum-A toxin injections for neurogenic detrusor overactivity: a prospective randomized study. J Urol.
263 Karsenty G, Reitz A, Lindemann G, et al. (2006). Persistence of therapeutic effect after repeated injections of botulinum toxin type A to treat incontinence due to neurogenic detrusor overactivity. Urology.
264 Kuo HC. (2004). Urodynamic evidence of effectiveness of botulinum A toxin injection in treatment of detrusor overactivity refractory to anticholinergic agents. Urology.
265 Brubaker L, Richter HE, Visco A, et al. (2008). Refractory idiopathic urge urinary incontinence and botulinum A injection. J Urol.
266 McHorney CA, Ware JE, Raczek AE. (1993). The MOS 36-Item Short-Form Health Survey (SF-36): II. Psychometric and clinical tests of validity in measuring physical and mental health constructs. Med Care.
267 Wagner TH, Patrick DL, Bavendam TG, et al. (1996). Quality of life of persons with urinary incontinence: development of a new measure. Urology.
268 Sorensen SS, Nielsen JB, Norgaard JP, et al. (1984). Changes in bladder volumes with repetition of water cystometry. Urol Res.
269 Wang AC, Wang YY, Chen MC. (2004). Single-blind, randomized trial of pelvic floor muscle training, biofeedback-assisted pelvic floor muscle training, and electrical stimulation in the management of overactive bladder. Urology.
270 Nabi G, Cody JD, Ellis G, et al. Anticholinergic drugs versus placebo for overactive bladder syndrome in adults. Cochrane Database Syst Rev.
271 Chapple CR, Khullar V, Gabriel Z, et al. (2008). The effects of antimuscarinic treatments in overactive bladder: an update of a systematic review and meta-analysis. Eur Urol.
272 D'Souza AO, Smith MJ, Miller LA, et al. (2008). Persistence, adherence, and switch rates among extended-release and immediate-release overactive bladder medications in a regional managed care plan. J Manag Care Pharm.
273 Balkrishnan R, Bhosle MJ, Camacho FT, et al. (2006). Predictors of medication adherence and associated health care costs in an older population with overactive bladder syndrome: a longitudinal cohort study. J Urol.
274 Lawrence M, Guay DR, Benson SR, et al. (2000). Immediate-release oxybutynin versus tolterodine in detrusor overactivity: a population analysis. Pharmacotherapy.
275 Yu YF, Nichol MB, Yu AP, et al. (2005). Persistence and adherence of medications for chronic overactive bladder/urinary incontinence in the california medicaid program. Value Health.