# Appendix E List of Peer Reviewers

We extend our appreciation to the members of the Technical Expert Panel (TEP) who provided advice and input during our research process. We identified technical experts on the topic of OAB in the fields of urology, urogynecology, gynecology, primary care, nursing, and patient advocacy to provide assistance during the project. The TEP was both an additional resource and a sounding board during the project. The TEP included twelve members serving as technical or clinical experts, including an AUA representative. To ensure robust, scientifically relevant work, we called on the TEP to provide reactions to work in progress and advice on substantive issues or possibly overlooked areas of research. TEP members are listed below (* also a peer reviewer):

- Roger Dmochowski, M.D.*
- Professor
- Vanderbilt University, Urologic surgery

- Catherine DuBeau, M.D.*
- Associate Professor, University of Chicago
- Director, Geriatric Continence Center

- Heddy Hubbard, Ph.D., M.P.H., R.N., F.A.A.N.*
- Director of Guidelines
- American Urological Association

- Melissa Lavender, M.B.A.
- Founder, Executive Director, Women’s Health Foundation

- Susan Meikle, M.D., M.S.P.H.
- NICHD, Project Scientist, Pelvic Floor Disorders Network

- Diane K. Newman, R.N.C., M.S.N., C.R.N.P, F.A.A.N.*
- Co-Director, Penn Center for Continence and Pelvic Health
- University of Pennsylvania

- Richard S. Pelman, M.D.*
- American Urological Association
- Bellevue Urology Associates

- Maureen G. Phipps, M.D., M.P.H.
- Associate Professor of Obstetrics/Gynecology
- Women & Infants Hospital of Rhode Island

- Neil Resnick, M.D.
- Professor and Chief, University of Pittsburgh Medical Center, Division of Geriatric Medicine
- Director, Institute on Aging

- Holly Richter, M.D., Ph.D.*
- Chief, Women’s Pelvic Medicine & Reconstructive Surgery
- University of Alabama-Birmingham

- Eric S. Rovner, M.D.*
- Associate Professor, Medical University of South Carolina Urology Services

- J. Christian Winters, M.D.
- Chairman and Professor, Department of Urology
- LSU Health Sciences Center

- Jennifer Wu, M.D., M.P.H.*
- Assistant Professor, Division of Urogynecology
- Duke University Medical Center