# Appendix D List of Excluded Studies

Excluded Articles

Full Text Article Exclusion Criteria Codes for Database

X-1A: Not OAB (including post-operative/iatrogenic)

X-1B: Stress or mixed incontinence

X-1C: Isolated nocturia

X-1D: Interstitial cystitis/painful bladder syndrome

X-1E: Pelvic organ prolapse

X-1F: Neurogenic conditions

X-1G: Basic science or anatomy only

X-1H: Imaging/diagnostic study only

X-1I: Other (including questionnaire validation studies, coping strategies, etc.)

X-2: Not original research

X-4: Less than 75% of study population are adult females

X-5: Non-ambulatory population

X-6: Ineligible study type

X-7: N <50

X-8: Non- US cost study/general cost of incontinence (not specifically OAB)

X-9: Treatment not currently available in the US

X-10: Unable to obtain full text of manuscript

## List of Excluded Studies

1 (1988). Terodiline and oxybutynin in detrusor instability. Drug Ther Bull.
2 (1993). Effects of terodiline on urinary incontinence among older non-institutionalized women. Terodiline in the Elderly American Multicenter Study Group. J Am Geriatr Soc.
3 (1999). Biofeedback, exercise for urge incontinence. Health News.
4 (1999). Overactive bladder. Harv Womens Health Watch.
5 (2000). Sacral nerve stimulation for the treatment of urinary urgency/frequency. Tecnologica MAP Suppl.
6 (2001). Detrol LA and Diropan XL for overactive bladder. Med Lett Drugs Ther.
7 (2001). Incontinence: an overview. N2N: Nurse2Nurse.
8 (2002). Don’t let elderly patients ‘put up with’ incontinence. Senior Care Management.
9 (2003). Behavior therapy and urge incontinence. Mayo Clin Health Lett.
10 (2003). Skin patch approved for treatment of overactive bladder. Mayo Clin Womens Healthsource.
11 (2004). Overactive bladder. Relief for urgency, frequency and incontinence. Mayo Clin Womens Healthsource.
12 (2004). Trospium chloride (Sanctura): another anticholinergic for overactive bladder. Med Lett Drugs Ther.
13 (2005). Innovations in overactive bladder treatment and the nursing home environment. Long-Term Care Interface.
14 (2007). Design of the Behavior Enhances Drug Reduction of Incontinence (BE-DRI) study. Contemp Clin Trials.
15 (2008). Appropriate pharmacotherapy for nocturia in elderly patients reduces urinary frequency, thereby improving sleep and health-related quality of life. Drugs & Therapy Perspectives.
16 Blander DS, Carpiniello VL, Harryhill JF, et al. (1999). Extraperitoneal laparoscopic urethropexy with Marlex mesh. Urology.
17 Aagaard J, Reuther K, Stimpel H. (1983). A comparison between the combination emepronium bromide/flavoxate and emepronium bromide in the treatment of detrusor instability. Urol Int.
18 Ab E, Dik P, Klijn AJ, et al. (2004). Detrusor overactivity in spina bifida: how long does it need to be treated?. Neurourol Urodyn.
19 Abarbanel J, Marcus EL. (2007). Impaired detrusor contractility in community-dwelling elderly presenting with lower urinary tract symptoms. Urology.
20 Abdel-Fattah M, Ramsay I, Barrington JW. (2007). A simple visual analogue scale to assess the quality of life in women with urinary incontinence. Eur J Obstet Gynecol Reprod Biol.
21 Abdel-Hady el S, Constantine G. (2005). Outcome of the use of tension-free vaginal tape in women with mixed urinary incontinence, previous failed surgery, or low valsalva pressure. J Obstet Gynaecol Res.
22 Aboseif S, Tamaddon K, Chalfin S, et al. (2002). Sacral neuromodulation as an effective treatment for refractory pelvic floor dysfunction. Urology.
23 Abrams P, Blaivas JG, Fowler CJ, et al. (2003). The role of neuromodulation in the management of urinary urge incontinence. BJU Int.
24 Abrams P, Kelleher C, Huels J, et al. (2008). Clinical relevance of health-related quality of life outcomes with darifenacin. BJU Int.
25 Abrams P, Klevmark B. (1996). Frequency volume charts: an indispensable part of lower urinary tract assessment. Scand J Urol Nephrol Suppl.
26 Abrams P, Malone-Lee J, Jacquetin B, et al. (2001). Twelve-month treatment of overactive bladder: efficacy and tolerability of tolterodine. Drugs Aging.
27 Abrams P, Swift S. (2005). Solifenacin is effective for the treatment of OAB dry patients: a pooled analysis. Eur Urol.
28 Addison R. (1999). Catheter valves: a special focus on the Bard Flip-Flo catheter. Br J Nurs.
29 Adekanmi OA, Freeman RM, Reed H, et al. (2003). Improving the diagnosis of genuine stress incontinence in symptomatic women with negative cough stress test: the Distal Urethral Electrical Conductance test (DUEC) revisited. Int Urogynecol J Pelvic Floor Dysfunct.
30 Agarwal A, Dhiraaj S, Singhal V, et al. (2006). Comparison of efficacy of oxybutynin and tolterodine for prevention of catheter related bladder discomfort: a prospective, randomized, placebo-controlled, double-blind study. Br J Anaesth.
31 Agarwal A, Yadav G, Gupta D, et al. (2008). Evaluation of intra-operative tramadol for prevention of catheter-related bladder discomfort: a prospective, randomized, double-blind study. Br J Anaesth.
32 Agnew G, Byrne P. (2004). The evaluation and treatment of female urinary incontinence--a comparison of clinical practice in the Republic of Ireland with the recommendations of the International Continence Society. Ir Med J.
33 Agwu UM, Umeora OU, Ejikeme BN. (2008). Patterns of menopausal symptoms and adaptive ability in a rural population in South-east Nigeria. J Obstet Gynaecol.
34 Ahlbeck G, Ulmsten U. (1986). A urethral valve for bladder drill in patients with motor urge incontinence. Gynecol Obstet Invest.
35 Ahlberg J, Edlund C, Wikkelso C, et al. (2002). Neurological signs are common in patients with urodynamically verified “idiopathic” bladder overactivity. Neurourol Urodyn.
36 Aitchison M, Carter R, Paterson P, et al. (1989). Is the treatment of urgency incontinence a placebo response? Results of a five-year follow-up. Br J Urol.
37 Akkad T, Pelzer A, Mitterberger M, et al. (2007). Influence of intravesical potassium on pelvic floor activity in women with overactive bladder syndrome: comparative urodynamics might provide better detection of dysfunctional voiding. BJU Int.
38 Akpinar H, Cetinel B, Demirkesen O, et al. (2000). Long-term results of Burch colposuspension. Int J Urol.
39 Ala-Ketola L, Kauppila A, Jouppila P, et al. (1981). Pre- and postoperative bead chain urethrocystography in female stress urinary incontinence. Acta Obstet Gynecol Scand.
40 Albo ME, Richter HE, Brubaker L, et al. (2007). Burch colposuspension versus fascial sling to reduce urinary stress incontinence. N Engl J Med.
41 Al-Buheissi S, Khasriya R, Maraj BH, et al. (2008). A simple validated scale to measure urgency. J Urol.
42 Alcalay M, Monga A, Stanton SL. (1995). Burch colposuspension: a 10–20 year follow up. Br J Obstet Gynaecol.
43 Alcalay M, Thompson PK, Boone TB. (2000). Ball urethroplasty combined with Marshall-Marchetti-Krantz urethropexy versus suburethral sling in patients with intrinsic sphincter deficiency and urethral hypermobility. Am J Obstet Gynecol.
44 Allen FJ, de Kock ML. (1993). Genito-urinary tuberculosis--experience with 52 urology inpatients. S Afr Med J.
45 Allen JH, McKenney JM, Stratton MA, et al. (1982). Antihypertensive effect of hydrochlorothiazide administered once or twice daily. Clin Pharm.
46 Alling Moller L, Lose G, Jorgensen T. (2000). Risk factors for lower urinary tract symptoms in women 40 to 60 years of age. Obstet Gynecol.
47 Alloussi S, Laval KU, Eckert R, et al. (1998). Trospium chloride (Spasmo-lyt) in patients with motor urge syndrome (detrusor instability): A double-blind, randomised, multicentre, placebo-controlled study. Journal of Clinical Research.
48 Alloussi S, Loew F, Mast GJ, et al. (1984). Treatment of detrusor instability of the urinary bladder by selective sacral blockade. Br J Urol.
49 Allsworth JE, Omicioli VA, Cunkelman JA, et al. (2008). Discussion: ‘Reproductive factors associated with nocturia and urgency’ by Tikkinen et al. Am J Obstet Gynecol.
50 Allsworth JE, Omicioli VA, Cunkelman JA, et al. (2008). Reproductive factors associated with nocturia and urgency: Tikkinen et al. Am J Obstet Gynecol.
51 Almeida FG, Bruschini H, Srougi M. (2004). Urodynamic and clinical evaluation of 91 female patients with urinary incontinence treated with perineal magnetic stimulation: 1-year followup. J Urol.
52 Almeida FG, Bruschini H, Srougi M. (2005). Correlation between urethral sphincter activity and Valsalva leak point pressure at different bladder distentions: revisiting the urethral pressure profile. J Urol.
53 Al-Mulhim AA, Al-Gazzar SA, Bahnassy AA. (2002). Conservative treatment of idiopathic detrusor instability in elderly women. Saudi Med J.
54 Alnaif B, Drutz HP. (2001). The prevalence of urinary and fecal incontinence in Canadian secondary school teenage girls: questionnaire study and review of the literature. Int Urogynecol J Pelvic Floor Dysfunct.
55 Alperin M, Abrahams-Gessel S, Wakamatsu MM. (2008). Development of de novo urge incontinence in women post sling: the role of preoperative urodynamics in assessing the risk. Neurourol Urodyn.
56 Altman D, Ekstrom A, Gustafsson C, et al. (2006). Risk of urinary incontinence after childbirth: a 10-year prospective cohort study. Obstet Gynecol.
57 Amarenco G, Ismael SS, Even-Schneider A, et al. (2003). Urodynamic effect of acute transcutaneous posterior tibial nerve stimulation in overactive bladder. J Urol.
58 Amarenco G, Ismael SS, Lagauche D, et al. (2005). Cough anal reflex: strict relationship between intravesical pressure and pelvic floor muscle electromyographic activity during cough. Urodynamic and electrophysiological study. J Urol.
59 Amaro JL, Gameiro MO, Kawano PR, et al. (2006). Intravaginal electrical stimulation: a randomized, double-blind study on the treatment of mixed urinary incontinence. Acta Obstet Gynecol Scand.
60 Amaro JL, Gameiro MO, Padovani CR. (2005). Effect of intravaginal electrical stimulation on pelvic floor muscle strength. Int Urogynecol J Pelvic Floor Dysfunct.
61 Amaro JL, Oliveira Gameiro MO, Padovani CR. (2003). Treatment of urinary stress incontinence by intravaginal electrical stimulation and pelvic floor physiotherapy. Int Urogynecol J Pelvic Floor Dysfunct.
62 Amayo EO, Kayima J, McLigeyo SO, et al. (1994). Autonomic nervous function in patients with chronic renal failure at the Kenyatta National Hospital. East Afr Med J.
63 Amoroso L, Pelliccioni G, Ghiselli R, et al. (2005). Sacral-neuromodulation CT-guided. Radiol Med (Torino).
64 Amundsen C, Lau M, English SF, et al. (1999). Do urinary symptoms correlate with urodynamic findings?. J Urol.
65 Amundsen CL, Flynn BJ, Webster GD. (2003). Anatomical correction of vaginal vault prolapse by uterosacral ligament fixation in women who also require a pubovaginal sling. J Urol.
66 Amundsen CL, Flynn BJ, Webster GD. (2003). Urethral erosion after synthetic and nonsynthetic pubovaginal slings: differences in management and continence outcome. J Urol.
67 Amundsen CL, Guralnick ML, Webster GD. (2000). Variations in strategy for the treatment of urethral obstruction after a pubovaginal sling procedure. J Urol.
68 Amundsen CL, Parsons M, Cardozo L, et al. (2006). Bladder diary volume per void measurements in detrusor overactivity. J Urol.
69 Amundsen CL, Parsons M, Tissot B, et al. (2007). Bladder diary measurements in asymptomatic females: functional bladder capacity, frequency, and 24-hr volume. Neurourol Urodyn.
70 Amundsen CL, Romero AA, Jamison MG, et al. (2005). Sacral neuromodulation for intractable urge incontinence: are there factors associated with cure?. Urology.
71 Amundsen CL, Visco AG, Ruiz H, et al. (2000). Outcome in 104 pubovaginal slings using freeze-dried allograft fascia lata from a single tissue bank. Urology.
72 Amundsen CL, Webster GD. (2002). Sacral neuromodulation in an older, urge-incontinent population. Am J Obstet Gynecol.
73 Andersen JR, Lose G, Norgaard M, et al. (1988). Terodiline, emepronium bromide or placebo for treatment of female detrusor overactivity? A randomised, double-blind, cross-over study. Br J Urol.
74 Andersen JT, Bradley WE. (1976). Abnormalities of detrusor and sphincter function in multiple sclerosis. Br J Urol.
75 Andersen LF, Agner T, Walter S, et al. (1987). Micturition pattern in hyperthyroidism and hypothyroidism. Urology.
76 Anderson RU. (2000). Efficacy and safety of oxybutynin for urinary urge incontinence. Clinical Geriatrics.
77 Andrades M, Paul R, Ambreen A, et al. (2004). Distribution of lower urinary tract symptoms (LUTS) in adult women. J Coll Physicians Surg Pak.
78 Anger JT, Amundsen CL, Webster GD. (2006). Obstruction after Burch colposuspension: a return to retropubic urethrolysis. Int Urogynecol J Pelvic Floor Dysfunct.
79 Anger JT, Litwin MS, Wang Q, et al. (2007). Complications of sling surgery among female Medicare beneficiaries. Obstet Gynecol.
80 Anger JT, Litwin MS, Wang Q, et al. (2007). The effect of age on outcomes of sling surgery for urinary incontinence. J Am Geriatr Soc.
81 Anger JT, Rodriguez LV, Wang Q, et al. (2007). The role of preoperative testing on outcomes after sling surgery for stress urinary incontinence. J Urol.
82 Anger JT, Saigal CS, Madison R, et al. (2006). Increasing costs of urinary incontinence among female Medicare beneficiaries. J Urol.
83 Apostolidis A, Brady CM, Yiangou Y, et al. (2005). Capsaicin receptor TRPV1 in urothelium of neurogenic human bladders and effect of intravesical resiniferatoxin. Urology.
84 Apostolidis A, Gonzales GE, Fowler CJ. (2006). Effect of intravesical Resiniferatoxin (RTX) on lower urinary tract symptoms, urodynamic parameters, and quality of life of patients with urodynamic increased bladder sensation. Eur Urol.
85 Apostolidis A, Popat R, Yiangou Y, et al. (2005). Decreased sensory receptors P2X3 and TRPV1 in suburothelial nerve fibers following intradetrusor injections of botulinum toxin for human detrusor overactivity. J Urol.
86 Appell RA. (1997). Clinical efficacy and safety of tolterodine in the treatment of overactive bladder: a pooled analysis. Urology.
87 Appell RA, Chancellor MB, Zobrist RH, et al. (2003). Pharmacokinetics, metabolism, and saliva output during transdermal and extended-release oral oxybutynin administration in healthy subjects. Mayo Clin Proc.
88 Appendino G, De Petrocellis L, Trevisani M, et al. (2005). Development of the first ultra-potent “capsaicinoid” agonist at transient receptor potential vanilloid type 1 (TRPV1) channels and its therapeutic potential. J Pharmacol Exp Ther.
89 Arena MG, Di Rosa AE, Arcudi L, et al. (1992). Voiding disorders in patients with cerebrovascular disease. Funct Neurol.
90 Arikan N, Soygur T, Selcuki M, et al. (1999). Role of magnetic resonance imaging in children with voiding dysfunction: retrospective analysis of 81 patients. Urology.
91 Armstrong RB, Dmochowski RR, Sand PK, et al. (2007). Safety and tolerability of extended-release oxybutynin once daily in urinary incontinence: combined results from two phase 4 controlled clinical trials. Int Urol Nephrol.
92 Arruda RM, Castro RA, Sartori MG, et al. (2003). Clinical and urodynamic evaluation of women with detrusor instability before and after functional pelvic floor electrostimulation. Clin Exp Obstet Gynecol.
93 Arunkalaivanan AS, Barrington JW. (2003). Randomized trial of porcine dermal sling (Pelvicol implant) vs. tension-free vaginal tape (TVT) in the surgical treatment of stress incontinence: a questionnaire-based study. Int Urogynecol J Pelvic Floor Dysfunct.
94 Arunkalaivanan AS, Mahomoud S, Howell M. (2004). Does posture affect cystometric parameters and diagnoses?. Int Urogynecol J Pelvic Floor Dysfunct.
95 Arya LA, Banks C, Gopal M, et al. (2008). Development and testing of a new instrument to measure fluid intake, output, and urinary symptoms: the questionnaire-based voiding diary. Am J Obstet Gynecol.
96 Arya LA, Myers DL, Jackson ND. (2000). Dietary caffeine intake and the risk for detrusor instability: a case-control study. Obstet Gynecol.
97 Ashken MH, Abrams PH, Lawrence WT. (1984). Stamey endoscopic bladder neck suspension for stress incontinence. Br J Urol.
98 Aslan G, Koseoglu H, Sadik O, et al. (2005). Sexual function in women with urinary incontinence. Int J Impot Res.
99 Atan A, Konety BR, Erickson JR, et al. (1999). Tolterodine for overactive bladder: time to onset of action, preferred dosage, and 9-month follow-up. Tech Urol.
100 Atan A, Konety BR, Nangia A, et al. (1999). Advantages and risks of ileovesicostomy for the management of neuropathic bladder. Urology.
101 Athanasiou S, Anstaklis A, Betsi GI, et al. (2007). Clinical and urodynamic parameters associated with history of urinary tract infections in women. Acta Obstet Gynecol Scand.
102 Attanucci CA, Ball HG, Zweizig SL, et al. (2004). Differences in symptoms between patients with benign and malignant ovarian neoplasms. Am J Obstet Gynecol.
103 Awad SA, Al-Zahrani HM, Gajewski JB, et al. (1998). Long-term results and complications of augmentation ileocystoplasty for idiopathic urge incontinence in women. Br J Urol.
104 Awad SA, Flood HD, Acker KL. (1988). The significance of prior anti-incontinence surgery in women who present with urinary incontinence. J Urol.
105 Awad SA, Gajewski JB, Katz NO, et al. (1992). Final diagnosis and therapeutic implications of mixed symptoms of urinary incontinence in women. Urology.
106 Awad SA, Gajewski JB, Sogbein SK, et al. (1984). Relationship between neurological and urological status in patients with multiple sclerosis. J Urol.
107 Awad SA, McGinnis RH. (1983). Factors that influence the incidence of detrusor instability in women. J Urol.
108 Axelsen SM, Bek KM, Petersen LK. (2007). Urodynamic and ultrasound characteristics of incontinence after radical hysterectomy. Neurourol Urodyn.
109 Babu R. (2006). Effectiveness of tolterodine in nonneurogenic voiding dysfunction. Indian Pediatr.
110 Bachmann G. (1995). The estradiol vaginal ring--a study of existing clinical data. Maturitas.
111 Bachmann G. (1995). Urogenital ageing: an old problem newly recognized. Maturitas.
112 Backhouse M, Harding L. (2006). Do males diagnosed with Duchenne muscular dystrophy (DMD) unnecessarily suffer bowel and bladder problems?. Australian & New Zealand Continence Journal.
113 Badawi JK, Ding A, Bross S. (2008). Inhibitory effects of different ATP-sensitive potassium channel openers on electrically generated and carbachol-induced contractions of porcine and human detrusor muscle. Fundam Clin Pharmacol.
114 Bade JJ, Laseur M, Nieuwenburg A, et al. (1997). A placebo-controlled study of intravesical pentosanpolysulphate for the treatment of interstitial cystitis. Br J Urol.
115 Bael A, Lax H, de Jong TP, et al. (2008). The relevance of urodynamic studies for Urge syndrome and dysfunctional voiding: a multicenter controlled trial in children. J Urol.
116 Baerheim A, Digranes A, Jureen R, et al. (2003). Generalized symptoms in adult women with acute uncomplicated lower urinary tract infection: an observational study. MedGenMed.
117 Bafghi A, Benizri EI, Trastour C, et al. (2005). Multifilament polypropylene mesh for urinary incontinence: 10 cases of infections requiring removal of the sling. BJOG.
118 Bafghi A, Valerio L, Benizri EI, et al. (2005). Comparison between monofilament and multifilament polypropylene tapes in urinary incontinence. Eur J Obstet Gynecol Reprod Biol.
119 Bagger PV, Fischer-Rasmussen W, Hansen R. (1985). Emepronium carrageenate: clinical effects and urinary excretion in treatment of female urge incontinence. Scand J Urol Nephrol.
120 Bagi P, Biering-Sorensen F. (2004). Botulinum toxin A for treatment of neurogenic detrusor overactivity and incontinence in patients with spinal cord lesions. Scand J Urol Nephrol.
121 Bai SW, Jang JB, Lee DY, et al. (2002). Uterine arterial embolization for the treatment of uterine leiomyomas. Yonsei Med J.
122 Bai SW, Jung HJ, Jeon MJ, et al. (2007). Surgical repair of anterior wall vaginal defects. Int J Gynaecol Obstet.
123 Bai SW, Park SH, Chung DJ, et al. (2005). The significance of bladder trabeculation in the female lower urinary system: an objective evaluation by urodynamic studies. Yonsei Med J.
124 Baigis-Smith J, Smith DA, Rose M, et al. (1989). Managing urinary incontinence in community-residing elderly persons. Gerontologist.
125 Bakas P, Liapis A, Giner M, et al. (2006). Quality of life in relation to TVT procedure for the treatment of stress urinary incontinence. Acta Obstet Gynecol Scand.
126 Balat A, Sarica K, Cekmen M, et al. (2003). Adrenomedullin and nitric oxide in children with detrusor instability. Pediatr Nephrol.
127 Ballert KN, Kanofsky JA, Nitti VW. (2008). Effect of tension-free vaginal tape and TVT-obturator on lower urinary tract symptoms other than stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
128 Bano F, Barrington JW. (2005). Serum calcium and magnesium levels in women with detrusor overactivity. J Obstet Gynaecol.
129 Baraza W, Boereboom C, Shorthouse A, et al. (2008). The long-term efficacy of fissurectomy and botulinum toxin injection for chronic anal fissure in females. Dis Colon Rectum.
130 Barbalias GA, Nikiforidis G, Liatsikos EN. (1998). Vesicourethral dysfunction associated with multiple sclerosis: clinical and urodynamic perspectives. J Urol.
131 Barber MD, Gustilo-Ashby AM, Chen CC, et al. (2006). Perioperative complications and adverse events of the MONARC transobturator tape, compared with the tension-free vaginal tape. Am J Obstet Gynecol.
132 Barber MD, Kleeman S, Karram MM, et al. (2008). Transobturator tape compared with tension-free vaginal tape for the treatment of stress urinary incontinence: a randomized controlled trial. Obstet Gynecol.
133 Barber MD, Visco AG, Wyman JF, et al. (2002). Sexual function in women with urinary incontinence and pelvic organ prolapse. Obstet Gynecol.
134 Barnes NM, Dmochowski RR, Park R, et al. (2002). Pubovaginal sling and pelvic prolapse repair in women with occult stress urinary incontinence: effect on postoperative emptying and voiding symptoms. Urology.
135 Barrero R, Fijo J, Fernandez-Hurtado M, et al. (2007). Vesicoureteral reflux after kidney transplantation in children. Pediatr Transplant.
136 Barroso U, Jednak R, Barthold JS, et al. (2001). Outcome of ureteral reimplantation in children with the urge syndrome. J Urol.
137 Bar-Sela S, Levy M, Westin JB, et al. (1992). Medical findings in nickel-cadmium battery workers. Isr J Med Sci.
138 Barthold JS, Martin-Crespo R, Kryger JV, et al. (1999). Quantitative nuclear cystography does not predict outcome in patients with primary vesicoureteral reflux. J Urol.
139 Bary PR, Moisey CU, Stephenson TP, et al. (1981). The urodynamic and subjective results of treatment of detrusor instability with oxybutynin chloride. Prog Clin Biol Res.
140 Baselli EC, Brandes SB, Luthin GR, et al. (1999). The effect of pregnancy and contractile activity on bladder muscarinic receptor subtypes. Neurourol Urodyn.
141 Basok EK, Yildirim A, Atsu N, et al. (2008). Cadaveric fascia lata versus intravaginal slingplasty for the pubovaginal sling: surgical outcome, overall success and patient satisfaction rates. Urol Int.
142 Basok EK, Yildirim A, Atsu N, et al. (2006). The surgical results of the pubovaginal sling procedure using Intravaginal Slingplasty (IVS) for stress urinary incontinence. Int Urol Nephrol.
143 Bassi P, De Marco V, Tavolini IM, et al. (2005). Pharmacokinetic study of intravesical gemcitabine in carcinoma in situ of the bladder refractory to bacillus Calmette-Guerin therapy. Urol Int.
144 Bates CP, Whiteside CG, Turner-Warwick R. (1970). Synchronous cine-pressure-flow-cysto-urethrography with special reference to stress and urge incontinence. Br J Urol.
145 Batista JE, Caffaratti J, Arano P, et al. (1998). The reliability of cysto-urethrographic signs in the diagnosis of detrusor instability in children. Br J Urol.
146 Batra AK, Mathews R, Lopresti A. (1997). Initial experience with the modified vaginal wall sling in the treatment of female stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
147 Bauer SB, Reda EF, Colodny AH, et al. (1986). Detrusor instability: a delayed complication in association with the artificial sphincter. J Urol.
148 Beck RP. (1980). Urinary stress incontinence. S Afr Med J.
149 Beck RP, McCormick S, Nordstrom L. (1988). The fascia lata sling procedure for treating recurrent genuine stress incontinence of urine. Obstet Gynecol.
150 Beck RP, McCormick S, Nordstrom L. (1991). A 25-year experience with 519 anterior colporrhaphy procedures. Obstet Gynecol.
151 Beck RP, Warren KG, Whitman P. (1981). Urodynamic studies in female patients with multiple sclerosis. Am J Obstet Gynecol.
152 Beco J. (2008). Interest of retro-anal levator plate myorrhaphy in selected cases of descending perineum syndrome with positive anti-sagging test. BMC Surg.
153 Beer AM, Fey S, Walch S, et al. (2001). The effect of peat components on endocrine and immunological parameters and on trace elements--results of two pilot studies. Clin Lab.
154 Beier-Holgersen R, Kirkeby LT, Nordling J. (1994). ‘Clam’ ileocystoplasty. Scand J Urol Nephrol.
155 Beisland HO, Fossberg E. (1985). The effects of terodiline and meladrazine on severe motor urge incontinence in geriatric patients. J Am Geriatr Soc.
156 Bell DA, Collie D, Statham PF. (2007). Cauda equina syndrome: what is the correlation between clinical assessment and MRI scanning?. Br J Neurosurg.
157 Belman AB. (1978). The clinical significant of cystitis cystica in girls: results of a prospective study. J Urol.
158 Benassi L, Bocchialini E, Bertelli M, et al. (2002). Risk of genital prolapse and urinary incontinence due to pregnancy and delivery. A prospective study. Minerva Ginecol.
159 Benedetti-Panici P, Zullo MA, Plotti F, et al. (2004). Long-term bladder function in patients with locally advanced cervical carcinoma treated with neoadjuvant chemotherapy and type 3–4 radical hysterectomy. Cancer.
160 Bennett N, O’Leary M, Patel AS, et al. (2004). Can higher doses of oxybutynin improve efficacy in neurogenic bladder?. J Urol.
161 Benson JT. (2000). Sacral nerve stimulation results may be improved by electrodiagnostic techniques. Int Urogynecol J Pelvic Floor Dysfunct.
162 Bent AE, Gousse AE, Hendrix SL, et al. (2005). Validation of a two-item quantitative questionnaire for the triage of women with urinary incontinence. Obstet Gynecol.
163 Bent AE, Gousse AE, Hendrix SL, et al. (2008). Duloxetine compared with placebo for the treatment of women with mixed urinary incontinence. Neurourol Urodyn.
164 Bent AE, Richardson DA, Ostergard DR. (1983). Diagnosis of lower urinary tract disorders in postmenopausal patients. Am J Obstet Gynecol.
165 Bent AE, Sand PK, Ostergard DR, et al. (1995). Transvaginal electrical stimulation in the treatment of genuine stress incontinence and detrusor instability... This article has been reprinted from the International Urogynecology Journal, Vol. 4, #1, 1993 with permission of Springer Virag London Ltd. Journal of Urological Nursing.
166 Bergman A, Bader K. (1990). Reliability of the patient’s history in the diagnosis of urinary incontinence. Int J Gynaecol Obstet.
167 Bergman A, Ballard CA, Platt LD. (1988). Ultrasonic evaluation of urethrovesical junction in women with stress urinary incontinence. J Clin Ultrasound.
168 Bergman A, Bhatia NN, Hasen J. (1984). Effect of thyroid releasing hormone on bladder and urethral pressures. Br J Urol.
169 Bergman A, Bhatia NN, Hasen J. (1984). Urinary urgency and thyrotropin-releasing hormone. Am J Obstet Gynecol.
170 Bergman A, Koonings PP, Ballard CA. (1989). Detrusor instability. Is the bladder the cause or the effect?. J Reprod Med.
171 Bergman A, Stanczyk FZ, Lobo RA. (1991). The role of prostaglandins in detrusor instability. Am J Obstet Gynecol.
172 Bergman J, Elia G. (1999). Effects of the menstrual cycle on urodynamic work-up: should we change our practice?. Int Urogynecol J Pelvic Floor Dysfunct.
173 Bernardi R, Perin C, Becker FL, et al. (2002). Effect of pilocarpine mouthwash on salivary flow. Braz J Med Biol Res.
174 Bharucha AE, Locke GR, Zinsmeister AR, et al. (2006). Differences between painless and painful constipation among community women. Am J Gastroenterol.
175 Bharucha AE, Seide B, Guan Z, et al. (2008). Effect of tolterodine on gastrointestinal transit and bowel habits in healthy subjects. Neurogastroenterol Motil.
176 Bhatia NN, Bergman A. (1988). Urinary urgency following administration of thyrotropin releasing hormone during simultaneous urethrocystometry. Urology.
177 Bhattacharya S, Mollison J, Pinion S, et al. (1996). A comparison of bladder and ovarian function two years following hysterectomy or endometrial ablation. Br J Obstet Gynaecol.
178 Bidmead J, Cardozo L, McLellan A, et al. (2001). A comparison of the objective and subjective outcomes of colposuspension for stress incontinence in women. BJOG.
179 Bihrle W, Tarantino AF. (1990). Complications of retropubic bladder neck suspension. Urology.
180 Billington A. (1999). Incontinence in older women. Elderly Care.
181 Bing MH, Moller LA, Jennum P, et al. (2007). Pathophysiological aspects of nocturia in a danish population of men and women age 60 to 80 years. J Urol.
182 Birch BR, Miller RA. (1995). Primary nocturnal enuresis: a urodynamic study spanning three generations. Scand J Urol Nephrol.
183 Birder LA, Wolf-Johnston A, Griffiths D, et al. (2007). Role of urothelial nerve growth factor in human bladder function. Neurourol Urodyn.
184 Birns J, Lukkari E, Malone-Lee JG. (2000). A randomized controlled trial comparing the efficacy of controlled-release oxybutynin tablets (10 mg once daily) with conventional oxybutynin tablets (5 mg twice daily) in patients whose symptoms were stabilized on 5 mg twice daily of oxybutynin. BJU Int.
185 Bjornsdottir LT, Geirsson RT, Jonsson PV. (1998). Urinary incontinence and urinary tract infections in octogenarian women. Acta Obstet Gynecol Scand.
186 Black N, Griffiths J, Pope C, et al. (1997). Impact of surgery for stress incontinence on morbidity: cohort study. BMJ.
187 Blackford HN, Murray K, Stephenson TP, et al. (1984). Results of transvesical infiltration of the pelvic plexuses with phenol in 116 patients. Br J Urol.
188 Blaivas JG, Bhimani G, Labib KB. (1979). Vesicourethral dysfunction in multiple sclerosis. J Urol.
189 Blaivas JG, Groutz A, Verhaaren M. (2001). Does the method of cystometry affect the incidence of involuntary detrusor contractions? A prospective randomized urodynamic study. Neurourol Urodyn.
190 Blaivas JG, Heritz DM, Romanzi LJ. (1995). Early versus late repair of vesicovaginal fistulas: vaginal and abdominal approaches. J Urol.
191 Blaivas JG, Jacobs BZ. (1991). Pubovaginal fascial sling for the treatment of complicated stress urinary incontinence. J Urol.
192 Blaivas JG, Olsson CA. (1988). Stress incontinence: classification and surgical approach. J Urol.
193 Blaivas JG, Panagopoulos G, Weiss JP, et al. (2007). Validation of the overactive bladder symptom score. J Urol.
194 Blaivas JG, Panagopoulos G, Weiss JP, et al. (2007). The urgency perception score: validation and test-retest. J Urol.
195 Blaivas JG, Weiss JP, Desai P, et al. (2005). Long-term followup of augmentation enterocystoplasty and continent diversion in patients with benign disease. J Urol.
196 Blander DS, Carpiniello VL, Harryhill JF, et al. (1999). Extraperitoneal laparoscopic urethropexy with Marlex mesh. Urology.
197 Blatt AH, Titus J, Chan L. (2008). Ultrasound measurement of bladder wall thickness in the assessment of voiding dysfunction. J Urol.
198 Blok BF, Groen J, Bosch JL, et al. (2006). Different brain effects during chronic and acute sacral neuromodulation in urge incontinent patients with implanted neurostimulators. BJU Int.
199 Blok BF, Sturms LM, Holstege G. (1998). Brain activation during micturition in women. Brain.
200 Bo K, Borgen JS. (2001). Prevalence of stress and urge urinary incontinence in elite athletes and controls. Med Sci Sports Exerc.
201 Bo K, Talseth T. (1996). Long-term effect of pelvic floor muscle exercise 5 years after cessation of organized training. Obstet Gynecol.
202 Bodelsson G, Henriksson L, Osser S, et al. (2002). Short term complications of the tension free vaginal tape operation for stress urinary incontinence in women. BJOG.
203 Boemers TM, van Gool JD, de Jong TP, et al. (1994). Lower urinary tract dysfunction in children with benign sacrococcygeal teratoma. J Urol.
204 Bolukbas N, Vural M, Karan A, et al. (2005). Effectiveness of functional magnetic versus electrical stimulation in women with urinary incontinence. Europa Medicophysica.
205 Bombier L, Freeman RM, Perkins EP, et al. (2002). Why do women have voiding dysfunction and de novo detrusor instability after colposuspension?. BJOG.
206 Bombieri L, Freeman RM. (2003). Do bladder neck position and amount of elevation influence the outcome of colposuspension?. BJOG.
207 Bond E, Dorey G, Eckford S, et al. (2004). The role of pelvic floor muscle exercises in reducing surgical management of women with stress incontinence: a clinical audit. Journal of the Association of Chartered Physiotherapists in Women’s Health.
208 Bonney WW, Gupta S, Hunter DR, et al. (1997). Bladder dysfunction in schizophrenia. Schizophr Res.
209 Borawski KM, Foster RT, Webster GD, et al. (2007). Predicting implantation with a neuromodulator using two different test stimulation techniques: A prospective randomized study in urge incontinent women. Neurourol Urodyn.
210 Borchert VE, Czyborra P, Fetscher C, et al. (2004). Extracts from Rhois aromatica and Solidaginis virgaurea inhibit rat and human bladder contraction. Naunyn Schmiedebergs Arch Pharmacol.
211 Bordman R, Telner D, Jackson B, et al. (2007). Step-by-step approach to managing pelvic organ prolapse: information for physicians. Can Fam Physician.
212 Borello-France D, Burgio KL. (2004). Nonsurgical treatment of urinary incontinence. Clin Obstet Gynecol.
213 Borello-France D, Dusi J, O’Leary M, et al. (2008). Test-retest reliability of the Urge-Urinary Distress Inventory and Female Sexual Function Index in women with multiple sclerosis. Urol Nurs.
214 Borello-France D, Leng W, O’Leary M, et al. (2004). Bladder and sexual function among women with multiple sclerosis. Mult Scler.
215 Borer JG, Gargollo PC, Kinnamon DD, et al. (2005). Bladder growth and development after complete primary repair of bladder exstrophy in the newborn with comparison to staged approach. J Urol.
216 Borrie MJ, Campbell AJ, Caradoc-Davies TH, et al. (1986). Urinary incontinence after stroke: a prospective study. Age Ageing.
217 Borup K, Nielsen JB. (2002). Results in 32 women operated for genuine stress incontinence with the pubovaginal sling procedure ad modum Ed McGuire. Scand J Urol Nephrol.
218 Borzyskowski M, Mundy AR. (1987). Videourodynamic assessment of diurnal urinary incontinence. Arch Dis Child.
219 Bosch JL, Groen J. (1995). Sacral (S3) segmental nerve stimulation as a treatment for urge incontinence in patients with detrusor instability: results of chronic electrical stimulation using an implantable neural prosthesis. J Urol.
220 Bosch JL, Groen J. (1998). Neuromodulation: urodynamic effects of sacral (S3) spinal nerve stimulation in patients with detrusor instability or detrusor hyperflexia. Behav Brain Res.
221 Bosch JL, Groen J. (2000). Sacral nerve neuromodulation in the treatment of patients with refractory motor urge incontinence: long-term results of a prospective longitudinal study. J Urol.
222 Botros SM, Abramov Y, Goldberg RP, et al. (2005). Detrusor overactivity and urge urinary incontinence [corrected] following midurethral versus bladder sling procedures. Am J Obstet Gynecol.
223 Botros SM, Miller JJ, Goldberg RP, et al. (2007). Detrusor overactivity and urge urinary incontinence following trans obturator versus midurethral slings. Neurourol Urodyn.
224 Bower WF, Moore KH, Adams RD. (2001). A pilot study of the home application of transcutaneous neuromodulation in children with urgency or urge incontinence. J Urol.
225 Bower WF, Moore KH, Adams RD, et al. (1998). A urodynamic study of surface neuromodulation versus sham in detrusor instability and sensory urgency. J Urol.
226 Bower WF, Sit FK, Yeung CK. (2006). Nocturnal enuresis in adolescents and adults is associated with childhood elimination symptoms. J Urol.
227 Bower WF, Yip SK, Yeung CK. (2005). Dysfunctional elimination symptoms in childhood and adulthood. J Urol.
228 Boyington AR, Dougherty MC, Phetrasuwan S. (2005). Effectiveness of a computer-based system to deliver a continence health promotion intervention. J Wound Ostomy Continence Nurs.
229 Bozkurt N, Ozkan S, Korucuoglu U, et al. (2007). Urogenital symptoms of postmenopausal women in Turkey. Menopause.
230 Bradley CS, Kennedy CM, Nygaard IE. (2005). Pelvic floor symptoms and lifestyle factors in older women. J Womens Health (Larchmt).
231 Bradshaw HD, Barker AT, Radley SC, et al. (2003). The acute effect of magnetic stimulation of the pelvic floor on involuntary detrusor activity during natural filling and overactive bladder symptoms. BJU Int.
232 Bradshaw HD, Radley SC, Rosario DJ, et al. (2005). Towards a better understanding of involuntary detrusor activity. BJU Int.
233 Bradway C, Coyne KS, Irwin D, et al. (2008). Lower urinary tract symptoms in women-a common but neglected problem. J Am Acad Nurse Pract.
234 Bramble FJ. (1982). The treatment of adult enuresis and urge incontinence by enterocystoplasty. Br J Urol.
235 Bratt H, Salvesen KA, Eriksen BC, et al. (1998). Long-term effects ten years after maximal electrostimulation of the pelvic floor in women with unstable detrusor and urge incontinence. Acta Obstet Gynecol Scand Suppl.
236 Braun PM, Boschert J, Bross S, et al. (1999). Tailored laminectomy: a new technique for neuromodulator implantation. J Urol.
237 Breen JM, Geer BE, May GE. (1997). The fascia lata suburethral sling for treating recurrent urinary stress incontinence. Am J Obstet Gynecol.
238 Briel RC. (1986). Follow-up of a new modification of the Marshall-Marchetti-Krantz (MMK) procedure. Arch Gynecol.
239 Britton S. (2006). Benefits of inclusive continence assessments for sexual health. Nurs Times.
240 Brock JW. (1994). The frequency and frequency dysuria syndromes of childhood: hypercalciuria as a possible etiology. Urology.
241 Brocklehurst JC. (1993). Urinary incontinence in the community--analysis of a MORI poll. BMJ.
242 Bross S, Braun PM, Michel MS, et al. (2003). Bladder wall tension during physiological voiding and in patients with an unstable detrusor or bladder outlet obstruction. BJU Int.
243 Bross S, Honeck P, Kwon ST, et al. (2007). Correlation between motor function and lower urinary tract dysfunction in patients with infantile cerebral palsy. Neurourol Urodyn.
244 Brown JS. (2002). Epidemiology and changing demographics of overactive bladder: a focus on the postmenopausal woman. Geriatrics.
245 Brown JS, Bradley CS, Subak LL, et al. (2006). The sensitivity and specificity of a simple test to distinguish between urge and stress urinary incontinence. Ann Intern Med.
246 Brown JS, Grady D, Ouslander JG, et al. (1999). Prevalence of urinary incontinence and associated risk factors in postmenopausal women. Heart & Estrogen/Progestin Replacement Study (HERS) Research Group. Obstet Gynecol.
247 Brown JS, McNaughton KS, Wyman JF, et al. (2003). Measurement characteristics of a voiding diary for use by men and women with overactive bladder. Urology.
248 Brown JS, Posner SF, Stewart AL. (1999). Urge incontinence: new health-related quality of life measures. J Am Geriatr Soc.
249 Brown JS, Subak LL, Gras J, et al. (1998). Urge incontinence: the patient’s perspective. J Womens Health.
250 Brown JS, Vittinghoff E, Kanaya AM, et al. (2001). Urinary tract infections in postmenopausal women: effect of hormone therapy and risk factors. Obstet Gynecol.
251 Brown JS, Vittinghoff E, Wyman JF, et al. (2000). Urinary incontinence: does it increase risk for falls and fractures? Study of Osteoporotic Fractures Research Group. J Am Geriatr Soc.
252 Brown K, Hilton P. (1999). The incidence of detrusor instability before and after colposuspension: a study using conventional and ambulatory urodynamic monitoring. BJU Int.
253 Brubaker L. (2006). Clinical advances in urogynecology. Minerva Ginecol.
254 Brubaker L, Benson JT, Bent A, et al. (1997). Transvaginal electrical stimulation for female urinary incontinence. Am J Obstet Gynecol.
255 Brubaker L, Cundiff GW, Fine P, et al. (2006). Abdominal sacrocolpopexy with Burch colposuspension to reduce urinary stress incontinence. N Engl J Med.
256 Brubaker L, FitzGerald MP. (2007). Nocturnal polyuria and nocturia relief in patients treated with solifenacin for overactive bladder symptoms. Int Urogynecol J Pelvic Floor Dysfunct.
257 Brubaker L, Kreder K, Richter HE, et al. (2006). Refractory urge urinary incontinence and botulinum A injection: the methods of the RUBI Trial. Journal of Applied Research.
258 Brubaker L, Richter HE, Visco A, et al. (2008). Refractory idiopathic urge urinary incontinence and botulinum A injection. J Urol.
259 Brusa L, Petta F, Pisani A, et al. (2006). Central acute D2 stimulation worsens bladder function in patients with mild Parkinson’s disease. J Urol.
260 Brusa L, Petta F, Pisani A, et al. (2007). Acute vs chronic effects of l-dopa on bladder function in patients with mild Parkinson disease. Neurology.
261 Bruschini H, Almeida FG, Srougi M. (2006). Upper and lower urinary tract evaluation of 104 patients with myelomeningocele without adequate urological management. World J Urol.
262 Bryan NP, Chapple CR. (2004). Frequency volume charts in the assessment and evaluation of treatment: how should we use them?. Eur Urol.
263 Buchsbaum GM, Chin M, Glantz C, et al. (2002). Prevalence of urinary incontinence and associated risk factors in a cohort of nuns. Obstet Gynecol.
264 Bukkapatnam R, Shah S, Raz S, et al. (2005). Anterior vaginal wall surgery in elderly patients: outcomes and assessment. Urology.
265 Bulmer PJ, James M, Ellis-Jones J, et al. (2001). A randomized trial comparing the effectiveness and preference of a touch-screen computer system with a leaflet for providing women with information on urinary symptoms suggestive of detrusor instability. BJU Int.
266 Bump RC. (2000). The urethrodetrusor facilitative reflex in women: results of urethral perfusion studies. Am J Obstet Gynecol.
267 Bump RC, Fantl JA, Hurt WG. (1988). Dynamic urethral pressure profilometry pressure transmission ratio determinations after continence surgery: understanding the mechanism of success, failure, and complications. Obstet Gynecol.
268 Bump RC, Hurt WG, Elser DM, et al. (1999). Understanding lower urinary tract function in women soon after bladder neck surgery. Continence Program for Women Research Group. Neurourol Urodyn.
269 Bump RC, Norton PA, Zinner NR, et al. (2003). Mixed urinary incontinence symptoms: urodynamic findings, incontinence severity, and treatment response. Obstet Gynecol.
270 Bump RC, Sugerman HJ, Fantl JA, et al. (1992). Obesity and lower urinary tract function in women: effect of surgically induced weight loss. Am J Obstet Gynecol.
271 Bunyavejchevin S. (2005). Risk factors of female urinary incontinence and overactive bladder in Thai postmenopausal women. J Med Assoc Thai.
272 Bunyavejchevin S. (2005). Urinary symptoms and quality of life changes in Thai women with overactive bladder after tolterodine treatment. J Med Assoc Thai.
273 Bunyavejchevin S. (2006). The impact of overactive bladder, stress and mixed urinary incontinence on quality of life in Thai postmenopausal women. J Med Assoc Thai.
274 Bunyavejchevin S, Veeranarapanich S. (2005). Quality of life assessment in Thai postmenopausal women with an overactive bladder. J Med Assoc Thai.
275 Bunyavejchevin S, Wisawasukmongchol W. (2005). Five years follow up of laparoscopic burch colposuspension for stress urinary incontinence in Thai women. J Med Assoc Thai.
276 Burgio KL. (1990). Behavioral training for stress and urge incontinence in the community. Gerontology.
277 Burgio KL. (2002). Influence of behavior modification on overactive bladder. Urology.
278 Burgio KL. (2004). Behavioral treatment options for urinary incontinence. Gastroenterology.
279 Burgio KL, Goode PS, Locher JL, et al. (2003). Predictors of outcome in the behavioral treatment of urinary incontinence in women. Obstet Gynecol.
280 Burgio KL, Nygaard IE, Richter HE, et al. (2007). Bladder symptoms 1 year after abdominal sacrocolpopexy with and without Burch colposuspension in women without preoperative stress incontinence symptoms. Am J Obstet Gynecol.
281 Burgio KL, Whitehead WE, Engel BT. (1985). Urinary incontinence in the elderly. Bladder-sphincter biofeedback and toileting skills training. Ann Intern Med.
282 Burke DM, Shackley DC, O’Reilly PH. (2002). The community-based morbidity of flexible cystoscopy. BJU Int.
283 Burkhard FC, Blick N, Hochreiter WW, et al. (2004). Urinary urgency and frequency, and chronic urethral and/or pelvic pain in females. Can doxycycline help?. J Urol.
284 Burkman RT. (2007). Transdermal hormonal contraception: benefits and risks. Am J Obstet Gynecol.
285 Burks FN, Diokno AC, Lajiness MJ, et al. (2008). Sacral neuromodulation reprogramming: is it an office burden?. Int Urogynecol J Pelvic Floor Dysfunct.
286 Burrows LJ, Meyn LA, Walters MD, et al. (2004). Pelvic symptoms in women with pelvic organ prolapse. Obstet Gynecol.
287 Burton JR, Pearce KL, Burgio KL, et al. (1988). Behavioral training for urinary incontinence in elderly ambulatory patients. J Am Geriatr Soc.
288 Butler RN, Maby JI, Montella JM, et al. (1999). Urinary incontinence: when to refer for procedural therapies. Geriatrics.
289 Byck DB, Varner RE, Clough C. (1994). Urinary complaints after modified Burch urethropexy: an analysis. Am J Obstet Gynecol.
290 Byrne RR, Auge BK, Kourambas J, et al. (2002). Routine ureteral stenting is not necessary after ureteroscopy and ureteropyeloscopy: a randomized trial. J Endourol.
291 Cain MP, Wu SD, Austin PF, et al. (2003). Alpha blocker therapy for children with dysfunctional voiding and urinary retention. J Urol.
292 Cameron-Strange A, Millard RJ. (1988). Management of refractory detrusor instability by transvesical phenol injection. Br J Urol.
293 Cammu H, Van Nylen M. (1995). Pelvic floor muscle exercises: 5 years later. Urology.
294 Candiani GB, Fedele L, Vercellini P, et al. (1992). Presacral neurectomy for the treatment of pelvic pain associated with endometriosis: a controlled study. Am J Obstet Gynecol.
295 Cantor TJ, Bates CP. (1980). A comparative study of symptoms and objective urodynamic findings in 214 incontinent women. Br J Obstet Gynaecol.
296 Cappellano F, Bertapelle P, Spinelli M, et al. (2001). Quality of life assessment in patients who undergo sacral neuromodulation implantation for urge incontinence: an additional tool for evaluating outcome. J Urol.
297 Caputo RM, Benson JT, McClellan E. (1993). Intravaginal maximal electrical stimulation in the treatment of urinary incontinence. J Reprod Med.
298 Caraballo R, Bologna RA, Lukban J, et al. (2001). Sacral nerve stimulation as a treatment for urge incontinence and associated pelvic floor disorders at a pelvic floor center: a follow-up study. Urology.
299 Carbone A, Gezeroglu H, Aloisi P, et al. (2001). Is aging a real risk factor for urological pathologies in men and women?. Arch Esp Urol.
300 Carbone A, Palleschi G, Conte A, et al. (2006). Gabapentin treatment of neurogenic overactive bladder. Clin Neuropharmacol.
301 Carbone A, Palleschi G, Parascani R, et al. (2002). Modulation of viscero-somatic H-reflex during bladder filling: a possible tool in the differential diagnosis of neurogenic voiding dysfunctions. Eur Urol.
302 Cardozo L. (1986). Urinary frequency and urgency. Br Med J (Clin Res Ed).
303 Cardozo L, Castro-Diaz D, Gittelman M, et al. (2006). Reductions in overactive bladder-related incontinence from pooled analysis of phase III trials evaluating treatment with solifenacin. Int Urogynecol J Pelvic Floor Dysfunct.
304 Cardozo L, Chapple CR, Toozs-Hobson P, et al. (2000). Efficacy of trospium chloride in patients with detrusor instability: a placebo-controlled, randomized, double-blind, multicentre clinical trial. BJU Int.
305 Cardozo L, Coyne KS, Versi E. (2005). Validation of the urgency perception scale. BJU Int.
306 Cardozo L, Dixon A. (2005). Increased warning time with darifenacin: a new concept in the management of urinary urgency. J Urol.
307 Cardozo L, Hextall A, Bailey J, et al. (1999). Colposuspension after previous failed incontinence surgery: a prospective observational study. Br J Obstet Gynaecol.
308 Cardozo L, Robinson D. (2002). Special considerations in premenopausal and postmenopausal women with symptoms of overactive bladder. Urology.
309 Cardozo LD, Abrams PD, Stanton SL, et al. (1978). Idiopathic bladder instability treated by biofeedback. Br J Urol.
310 Cardozo LD, Stanton SL. (1979). An objective comparison of the effects of parenterally administered drugs in patients suffering from detrusor instability. J Urol.
311 Cardozo LD, Stanton SL. (1980). A comparison between bromocriptine and indomethacin in the treatment of detrusor instability. J Urol.
312 Cardozo LD, Stanton SL. (1980). Genuine stress incontinence and detrusor instability--a review of 200 patients. Br J Obstet Gynaecol.
313 Cardozo LD, Stanton SL, Robinson H, et al. (1980). Evaluation of flurbiprofen in detrusor instability. Br Med J.
314 Cardozo LD, Stanton SL, Williams JE. (1979). Detrusor instability following surgery for genuine stress incontinence. Br J Urol.
315 Carey JM, Chon JK, Leach GE. (2003). Urethrolysis with Martius labial fat pad graft for iatrogenic bladder outlet obstruction. Urology.
316 Carey M, Fynes M, Murray C, et al. (2001). Sacral nerve root stimulation for lower urinary tract dysfunction: overcoming the problem of lead migration. BJU Int.
317 Carey MP, De Jong S, Friedhuber A, et al. (2000). A prospective evaluation of the pathogenesis of detrusor instability in women, using electron microscopy and immunohistochemistry. BJU Int.
318 Carey MP, Goh JT, Fynes MM, et al. (2002). Stress urinary incontinence after delayed primary closure of genitourinary fistula: a technique for surgical management. Am J Obstet Gynecol.
319 Carlson KV, Rome S, Nitti VW. (2001). Dysfunctional voiding in women. J Urol.
320 Carr LK, Walsh PJ, Abraham VE, et al. (1997). Favorable outcome of pubovaginal slings for geriatric women with stress incontinence. J Urol.
321 Carr LK, Webster GD. (1997). Voiding dysfunction following incontinence surgery: diagnosis and treatment with retropubic or vaginal urethrolysis. J Urol.
322 Carrico DJ, Peters KM, Diokno AC. (2008). Guided imagery for women with interstitial cystitis: results of a prospective, randomized controlled pilot study. J Altern Complement Med.
323 Carter JE. (1995). Laparoscopic bladder neck suspension. Endosc Surg Allied Technol.
324 Cartwright R, Elvy S, Cardozo L. (2007). Do women with female ejaculation have detrusor overactivity?. J Sex Med.
325 Castera R, Podesta ML, Ruarte A, et al. (2001). 10-Year experience with artificial urinary sphincter in children and adolescents. J Urol.
326 Castleden CM, Duffin HM, Asher MJ, et al. (1985). Factors influencing outcome in elderly patients with urinary incontinence and detrusor instability. Age Ageing.
327 Castleden CM, Duffin HM, Clarkson EJ. (1983). In vivo and in vitro studies on the effect of sodium antagonists on the bladder in man and rat. Age Ageing.
328 Castro NM, Freitas DM, Rodrigues W, et al. (2007). Urodynamic features of the voiding dysfunction in HTLV-1 infected individuals. Int Braz J Urol.
329 Cawley DM, Hendriks O. (1992). Evaluation of the Endomed CV 405 as a treatment for urinary incontinence. Physiotherapy.
330 Centonze D, Petta F, Versace V, et al. (2007). Effects of motor cortex rTMS on lower urinary tract dysfunction in multiple sclerosis. Mult Scler.
331 Cespedes RD. (2000). Anterior approach bilateral sacrospinous ligament fixation for vaginal vault prolapse. Urology.
332 Cespedes RD, Cross CA, McGuire EJ. (1996). Modified Ingelman-Sundberg bladder denervation procedure for intractable urge incontinence. J Urol.
333 Cetinel B, Akpinar H, Tufek I, et al. (1999). Bladder involvement in Behcet’s syndrome. J Urol.
334 Cetinel B, Demirkesen O, Onal B, et al. (2004). Are there any factors predicting the cure and complication rates of tension-free vaginal tape?. Int Urogynecol J Pelvic Floor Dysfunct.
335 Cetinel B, Demirkesen O, Tarcan T, et al. (2007). Hidden female urinary incontinence in urology and obstetrics and gynecology outpatient clinics in Turkey: what are the determinants of bothersome urinary incontinence and help-seeking behavior?. Int Urogynecol J Pelvic Floor Dysfunct.
336 Chai TC, Gray ML, Steers WD. (1998). The incidence of a positive ice water test in bladder outlet obstructed patients: evidence for bladder neural plasticity. J Urol.
337 Chai TC, Zhang C, Warren JW, et al. (2000). Percutaneous sacral third nerve root neurostimulation improves symptoms and normalizes urinary HB-EGF levels and antiproliferative activity in patients with interstitial cystitis. Urology.
338 Chaiken DC, Blaivas JG, Blaivas ST. (1993). Behavioral therapy for the treatment of refractory interstitial cystitis. J Urol.
339 Chaikin DC, Blaivas JG, Rosenthal JE, et al. (1999). Results of pubovaginal sling for stress incontinence: a prospective comparison of 4 instruments for outcome analysis. J Urol.
340 Chaikin DC, Groutz A, Blaivas JG. (2000). Predicting the need for anti-incontinence surgery in continent women undergoing repair of severe urogenital prolapse. J Urol.
341 Chaikin DC, Rosenthal J, Blaivas JG. (1998). Pubovaginal fascial sling for all types of stress urinary incontinence: long-term analysis. J Urol.
342 Chaisaeng S, Santingamkun A, Opanuraks J, et al. (2006). IQOL: translation & reliability for use with urinary incontinence patients in Thailand. J Med Assoc Thai.
343 Chaliha C, Bland JM, Monga A, et al. (2000). Pregnancy and delivery: a urodynamic viewpoint. BJOG.
344 Chaliha C, Digesu GA, Hutchings A, et al. (2005). Changes in urethral function with bladder filling in the presence of urodynamic stress incontinence and detrusor overactivity. Am J Obstet Gynecol.
345 Chaliha C, Digesu GA, Salvatore S, et al. (2006). Changes in urethral resistance in the presence of detrusor activity. Int Urogynecol J Pelvic Floor Dysfunct.
346 Chan CL, Scott SM, Williams NS, et al. (2005). Rectal hypersensitivity worsens stool frequency, urgency, and lifestyle in patients with urge fecal incontinence. Dis Colon Rectum.
347 Chan KM, Lim PH, Chee YC, et al. (1992). Urinary symptoms and urodynamic diagnosis of patients in one geriatric department. Ann Acad Med Singapore.
348 Chandi DD, Groenendijk PM, Venema PL. (2004). Functional extracorporeal magnetic stimulation as a treatment for female urinary incontinence: ‘the chair’. BJU Int.
349 Chandiramani VA, Peterson T, Duthie GS, et al. (1996). Urodynamic changes during therapeutic intravesical instillations of capsaicin. Br J Urol.
350 Chandra M, Saharia R, Hill V, et al. (2004). Prevalence of diurnal voiding symptoms and difficult arousal from sleep in children with nocturnal enuresis. J Urol.
351 Chandra M, Saharia R, Shi Q, et al. (2002). Giggle incontinence in children: a manifestation of detrusor instability. J Urol.
352 Chapple C, Steers W, Norton P, et al. (2005). A pooled analysis of three phase III studies to investigate the efficacy, tolerability and safety of darifenacin, a muscarinic M3 selective receptor antagonist, in the treatment of overactive bladder. BJU Int.
353 Chapple CR, Abrams P. (2005). Comparison of darifenacin and oxybutynin in patients with overactive bladder: assessment of ambulatory urodynamics and impact on salivary flow. Eur Urol.
354 Chapple CR, Arano P, Bosch JL, et al. (2004). Solifenacin appears effective and well tolerated in patients with symptomatic idiopathic detrusor overactivity in a placebo- and tolterodine-controlled phase 2 dose-finding study. BJU Int.
355 Chapple CR, Parkhouse H, Gardener C, et al. (1990). Double-blind, placebo-controlled, cross-over study of flavoxate in the treatment of idiopathic detrusor instability. Br J Urol.
356 Chapple CR, Patroneva A, Raines SR. (2006). Effect of an ATP-sensitive potassium channel opener in subjects with overactive bladder: a randomized, double-blind, placebo-controlled study (ZD0947IL/0004). Eur Urol.
357 Chartier-Kastler EJ, Denys P, Chancellor MB, et al. (2001). Urodynamic monitoring during percutaneous sacral nerve neurostimulation in patients with neurogenic detrusor hyperreflexia. Neurourol Urodyn.
358 Chartier-Kastler EJ, Mongiat-Artus P, Bitker MO, et al. (2000). Long-term results of augmentation cystoplasty in spinal cord injury patients. Spinal Cord.
359 Chartier-Kastler EJ, Ruud Bosch JL, Perrigot M, et al. (2000). Long-term results of sacral nerve stimulation (S3) for the treatment of neurogenic refractory urge incontinence related to detrusor hyperreflexia. J Urol.
360 Cheater FM, Baker R, Gillies C, et al. (2008). The nature and impact of urinary incontinence experienced by patients receiving community nursing services: a cross-sectional cohort study. Int J Nurs Stud.
361 Chen CS, Cheng CL. (2006). Nephrogenic adenoma of the urinary bladder: clinical experience and review of the literature. J Chin Med Assoc.
362 Chen CW, Huang KH, Liang HM, et al. (2004). A comparison of urodynamic parameters and lower urinary tract symptoms in urodynamic genuine stress incontinence women with or without stress urinary incontinence. Chang Gung Med J.
363 Chen GD, Hu SW, Chen YC, et al. (2003). Prevalence and correlations of anal incontinence and constipation in Taiwanese women. Neurourol Urodyn.
364 Chen GD, Lin LY, Gardner JD. (1997). The results of laparoscopic adhesiolysis for intractable urinary frequency. J Urol.
365 Chen GD, Lin LY, Wang PH, et al. (2002). Urinary tract dysfunction after radical hysterectomy for cervical cancer. Gynecol Oncol.
366 Chen YH, Kuo HC. (2004). Botulinum A toxin treatment of urethral sphincter pseudodyssynergia in patients with cerebrovascular accidents or intracranial lesions. Urol Int.
367 Chene G, Amblard J, Tardieu AS, et al. (2007). Long-term results of tension-free vaginal tape (TVT) for the treatment of female urinary stress incontinence. Eur J Obstet Gynecol Reprod Biol.
368 Chene G, Cotte B, Tardieu AS, et al. (2008). Clinical and ultrasonographic correlations following three surgical anti-incontinence procedures (TOT, TVT and TVT-O). Int Urogynecol J Pelvic Floor Dysfunct.
369 Cheon WC, Mak JH, Liu JY. (2003). Prospective randomised controlled trial comparing laparoscopic and open colposuspension. Hong Kong Med J.
370 Chertin B, Koulikov D, Abu-Arafeh W, et al. (2007). Treatment of nocturnal enuresis in children with attention deficit hyperactivity disorder. J Urol.
371 Cheshire WP, Tsuboi Y, Wszolek ZK. (2002). Physiologic assessment of autonomic dysfunction in pallidopontonigral degeneration with N279K mutation in the tau gene on chromosome 17. Auton Neurosci.
372 Chiaffarino F, Parazzini F, Lavezzari M, et al. (2003). Impact of urinary incontinence and overactive bladder on quality of life. Eur Urol.
373 Chiara G, Piccioni V, Perino M, et al. (1998). Psychological investigation in female patients suffering from urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
374 Chiarelli P. (2007). Urinary stress incontinence and overactive bladder symptoms in older women. Contemp Nurse.
375 Chin YK, Stanton SL. (1995). A follow up of silastic sling for genuine stress incontinence. Br J Obstet Gynaecol.
376 Chiu NC, Huang FY, Tsai TC. (1989). Urinary tract infections in children. Zhonghua Min Guo Xiao Er Ke Yi Xue Hui Za Zhi.
377 Choe JH, Choo MS, Lee KS. (2007). Symptom change in women with overactive bladder after extracorporeal magnetic stimulation: a prospective trial. Int Urogynecol J Pelvic Floor Dysfunct.
378 Choe JH, Choo MS, Lee KS. (2008). The impact of tension-free vaginal tape on overactive bladder symptoms in women with stress urinary incontinence: significance of detrusor overactivity. J Urol.
379 Choe JM. (2001). Preventing urethral obstruction using the 6-point fixation and weight-adjusted spacing nomogram during sling surgery. Int Urogynecol J Pelvic Floor Dysfunct.
380 Choe JM. (2002). Suprapubic sling adjustment: minimally invasive method of curing recurrent stress incontinence after sling surgery. J Urol.
381 Choe JM, Gallo ML, Staskin DR. (1999). A provocative maneuver to elicit cystometric instability: measuring instability at maximum infusion. J Urol.
382 Choe JM, Ogan K, Battino BS. (2000). Antimicrobial mesh versus vaginal wall sling: a comparative outcomes analysis. J Urol.
383 Choe JM, Ogan K, Bennett S. (2000). Antibacterial mesh sling: a prospective outcome analysis. Urology.
384 Choe JM, Staskin DR. (1999). Gore-Tex patch sling: 7 years later. Urology.
385 Choi JB, Kim YB, Kim BT, et al. (2005). Analysis of heart rate variability in female patients with overactive bladder. Urology.
386 Cholhan HJ, Lotze PM. (2004). Voiding function after a modified no-tension pubovaginal sling. Int Urogynecol J Pelvic Floor Dysfunct.
387 Cholhan HJ, Lotze PM. (2008). Urodynamic changes after tension-free sling procedures: Mycromesh-Plus vs TVT sling. Int Urogynecol J Pelvic Floor Dysfunct.
388 Chompootaweep S, Nunthapisud P, Trivijitsilp P, et al. (1998). The use of two estrogen preparations (a combined contraceptive pill versus conjugated estrogen cream) intravaginally to treat urogenital symptoms in postmenopausal Thai women: a comparative study. Clin Pharmacol Ther.
389 Choo MS, Song C, Kim JH, et al. (2005). Changes in overactive bladder symptoms after discontinuation of successful 3-month treatment with an antimuscarinic agent: a prospective trial. J Urol.
390 Chou EC, Blaivas JG, Chou LW, et al. (2008). Urodynamic characteristics of mixed urinary incontinence and idiopathic urge urinary incontinence. Neurourol Urodyn.
391 Chou EC, Flisser AJ, Panagopoulos G, et al. (2003). Effective treatment for mixed urinary incontinence with a pubovaginal sling. J Urol.
392 Chou TP, Gorton E, Stanton SL, et al. (2000). Can uroflowmetry patterns in women be reliably interpreted?. Int Urogynecol J Pelvic Floor Dysfunct.
393 Christman NJ, Oakley MG, Cronin SN. (2001). Developing and using preparatory information for women undergoing radiation therapy for cervical or uterine cancer. Oncol Nurs Forum.
394 Christmas TJ, Smith GL, Rickards D. (1997). Diagnosis and management of high-pressure peristaltic contractions in cystoplasties. Br J Urol.
395 Christoph F, Moschkowitsch A, Kempkensteffen C, et al. (2007). Long-term efficacy of tolterodine and patient compliance in pediatric patients with neurogenic detrusor overactivity. Urol Int.
396 Chu PS, Ma WK, Wong SC, et al. (2008). The destruction of the lower urinary tract by ketamine abuse: a new syndrome?. BJU Int.
397 Chuang YC, Thomas CA, Tyagi S, et al. (2008). Human urine with solifenacin intake but not tolterodine or darifenacin intake blocks detrusor overactivity. Int Urogynecol J Pelvic Floor Dysfunct.
398 Chung JM, Lee SD, Kang DI, et al. (2009). Prevalence and associated factors of overactive bladder in Korean children 5–13 years old: a nationwide multicenter study. Urology.
399 Chung SY, Franks M, Smith CP, et al. (2002). Technique of combined pubovaginal sling and cystocele repair using a single piece of cadaveric dermal graft. Urology.
400 Cindolo L, Salzano L, Rota G, et al. (2004). Tension-free transobturator approach for female stress urinary incontinence. Minerva Urol Nefrol.
401 Clarke B. (1992). Urethral instability. Aust N Z J Obstet Gynaecol.
402 Clarke B. (1997). The role of urodynamic assessment in the diagnosis of lower urinary tract disorders. Int Urogynecol J Pelvic Floor Dysfunct.
403 Clarke SJ, Forster DM, Thomas DG. (1979). Selective sacral neurectomy in the management of urinary incontinence due to detrusor instability. Br J Urol.
404 Clauw DJ, Schmidt M, Radulovic D, et al. (1997). The relationship between fibromyalgia and interstitial cystitis. J Psychiatr Res.
405 Clemens JQ, Stern JA, Bushman WA, et al. (1998). Long-term results of the Stamey bladder neck suspension: direct comparison with the Marshall-Marchetti-Krantz procedure. J Urol.
406 Clemons JL, Aguilar VC, Sokol ER, et al. (2005). Suburethral sling treatment of occult stress incontinence and intrinsic sphincter deficiency in women with severe vaginal prolapse of the anterior vs posterior/apical compartment. Am J Obstet Gynecol.
407 Clemons JL, Aguilar VC, Tillinghast TA, et al. (2004). Patient satisfaction and changes in prolapse and urinary symptoms in women who were fitted successfully with a pessary for pelvic organ prolapse. Am J Obstet Gynecol.
408 Cliff AM, Heatherwick B, Scoble J, et al. (2000). The effect of fasting or desmopressin before treatment on the concentration of mitomycin C during intravesical administration. BJU Int.
409 Close CE, Carr MC, Burns MW, et al. (1996). Interstitial cystitis in children. J Urol.
410 Clow WM. (1975). Effect of posture on bladder and urethral function in normal pregnancy. A preliminary report. Urol Int.
411 Clyne OJ, O’Sullivan O, Flood HD. (2005). Pubovaginal sling for urodynamic stress incontinence: effect on patient quality of life. Ir Med J.
412 Coates KW, Harris RL, Cundiff GW, et al. (1997). Uroflowmetry in women with urinary incontinence and pelvic organ prolapse. Br J Urol.
413 Cohen BL, Barboglio P, Gousse A. (2008). The impact of lower urinary tract symptoms and urinary incontinence on female sexual dysfunction using a validated instrument. J Sex Med.
414 Cohen BL, Rivera R, Barboglio P, et al. (2007). Safety and tolerability of sedation-free flexible cystoscopy for intradetrusor botulinum toxin-A injection. J Urol.
415 Cohen BL, Tunuguntla HS, Gousse A. (2006). Predictors of success for first stage neuromodulation: motor versus sensory response. J Urol.
416 Cohen HA, Nussinovitch M, Kauschansky A, et al. (1993). Extraordinary daytime urinary frequency in children. J Fam Pract.
417 Cole EE, Kaufman MR, Scarpero HM, et al. (2006). The effects of isolated posterior compartment defects on lower urinary tract symptoms and urodynamic findings. BJU Int.
418 Cole EE, Scarpero HM, Dmochowski RR. (2005). Are patient symptoms predictive of the diagnostic and/or therapeutic value of hydrodistention?. Neurourol Urodyn.
419 Collas DM, Malone-Lee JG. (1996). Age-associated changes in detrusor sensory function in women with lower urinary tract symptoms. Int Urogynecol J Pelvic Floor Dysfunct.
420 Collinet P, Ciofu C, Costa P, et al. (2008). The safety of the inside-out transobturator approach for transvaginal tape (TVT-O) treatment in stress urinary incontinence: French registry data on 984 women. Int Urogynecol J Pelvic Floor Dysfunct.
421 Colman S, Chapple C, Nitti V, et al. (2008). Validation of treatment benefit scale for assessing subjective outcomes in treatment of overactive bladder. Urology.
422 Colombo M, Maggioni A, Zanetta G, et al. (1996). Prevention of postoperative urinary stress incontinence after surgery for genitourinary prolapse. Obstet Gynecol.
423 Colombo M, Scalambrino S, Maggioni A, et al. (1994). Burch colposuspension versus modified Marshall-Marchetti-Krantz urethropexy for primary genuine stress urinary incontinence: a prospective, randomized clinical trial. Am J Obstet Gynecol.
424 Colombo M, Zanetta G, Vitobello D, et al. (1996). The Burch colposuspension for women with and without detrusor overactivity. Br J Obstet Gynaecol.
425 Combs AJ, Nitti VW. (1995). Significance of rectal contractions noted on multichannel urodynamics. Neurourol Urodyn.
426 Comperat E, Reitz A, Delcourt A, et al. (2006). Histologic features in the urinary bladder wall affected from neurogenic overactivity--a comparison of inflammation, oedema and fibrosis with and without injection of botulinum toxin type A. Eur Urol.
427 Congregado Ruiz B, Pena Outeirino XM, Campoy Martinez P, et al. (2004). Peripheral afferent nerve stimulation for treatment of lower urinary tract irritative symptoms. Eur Urol.
428 Constantinou CE. (1992). Pharmacologic treatment of detrusor incontinence with thiphenamil HCl. Urol Int.
429 Contreras Ortiz O, Lombardo RJ, Pellicari A. (1993). Non-invasive diagnosis of bladder instability using the Bladder Instability Discriminant Index (BIDI). Zentralbl Gynakol.
430 Cooper MJ, Cario G, Lam A, et al. (1996). A review of results in a series of 113 laparoscopic colposuspensions. Aust N Z J Obstet Gynaecol.
431 Corigliano T, Renella R, Robbiani A, et al. (2007). Isolated extraordinary daytime urinary frequency of childhood: a case series of 26 children in Switzerland. Acta Paediatr.
432 Cortesse A, Jacquetin B, Grise P, et al. (2007). Prospective multicenter clinical trial of Uretex Sup for surgical treatment of stress urinary incontinence. Int J Urol.
433 Cosimo O, Pierluigi P, Angelo ZM, et al. (1997). A clinical and urodynamic study of patients with varying degrees of cystocele. Maturitas.
434 Costantini E, Lazzeri M, Bini V, et al. (2008). Sensitivity and specificity of one-hour pad test as a predictive value for female urinary incontinence. Urol Int.
435 Costantini E, Mearini L, Mearini E, et al. (2005). Assessing outcome after a modified vaginal wall sling for stress incontinence with intrinsic sphincter deficiency. Int Urogynecol J Pelvic Floor Dysfunct.
436 Costello AJ, Crowe H, Agarwal D. (2000). Supratrigonal cystectomy and ileocystoplasty in management of interstitial cystitis. Aust N Z J Surg.
437 Cowan JA, McGirt MJ, Woodworth G, et al. (2005). The syndrome of hydrocephalus in young and middle-aged adults (SHYMA). Neurol Res.
438 Coyne K, Revicki D, Hunt T, et al. (2002). Psychometric validation of an overactive bladder symptom and health-related quality of life questionnaire: the OAB-q. Qual Life Res.
439 Coyne KS, Elinoff V, Gordon DA, et al. (2008). Relationships between improvements in symptoms and patient assessments of bladder condition, symptom bother and health-related quality of life in patients with overactive bladder treated with tolterodine. Int J Clin Pract.
440 Coyne KS, Margolis MK, Brewster-Jordan J, et al. (2007). Evaluating the impact of overactive bladder on sexual health in women: what is relevant?. J Sex Med.
441 Coyne KS, Margolis MK, Jumadilova Z, et al. (2007). Overactive bladder and women’s sexual health: what is the impact?. J Sex Med.
442 Coyne KS, Matza LS, Kopp Z, et al. (2006). The validation of the patient perception of bladder condition (PPBC): a single-item global measure for patients with overactive bladder. Eur Urol.
443 Coyne KS, Matza LS, Thompson C, et al. (2007). The responsiveness of the OAB-q among OAB patient subgroups. Neurourol Urodyn.
444 Coyne KS, Matza LS, Thompson CL. (2005). The responsiveness of the Overactive Bladder Questionnaire (OAB-q). Qual Life Res.
445 Coyne KS, Matza LS, Thompson CL, et al. (2006). Determining the importance of change in the overactive bladder questionnaire. J Urol.
446 Coyne KS, Payne C, Bhattacharyya SK, et al. (2004). The impact of urinary urgency and frequency on health-related quality of life in overactive bladder: results from a national community survey. Value Health.
447 Coyne KS, Sexton CC, Irwin DE, et al. (2008). The impact of overactive bladder, incontinence and other lower urinary tract symptoms on quality of life, work productivity, sexuality and emotional well-being in men and women: results from the EPIC study. BJU Int.
448 Coyne KS, Zhou Z, Bhattacharyya SK, et al. (2003). The prevalence of nocturia and its effect on health-related quality of life and sleep in a community sample in the USA. BJU Int.
449 Coyne KS, Zhou Z, Thompson C, et al. (2003). The impact on health-related quality of life of stress, urge and mixed urinary incontinence. BJU Int.
450 Coyne KS, Zyczynski T, Margolis MK, et al. (2005). Validation of an overactive bladder awareness tool for use in primary care settings. Adv Ther.
451 Cozzi F, Schiavetti A, Zani A, et al. (2008). The functional sequelae of sacrococcygeal teratoma: a longitudinal and cross-sectional follow-up study. J Pediatr Surg.
452 Craggs MD. (2005). Objective measurement of bladder sensation: use of a new patient-activated device and response to neuromodulation. BJU Int.
453 Creighton SM, Pearce JM, Robson I, et al. (1991). Sensory urgency: how full is your bladder?. Br J Obstet Gynaecol.
454 Creighton SM, Plevnik S, Stanton SL. (1991). Distal urethral electrical conductance (DUEC)--a preliminary assessment of its role as a quick screening test for incontinent women. Br J Obstet Gynaecol.
455 Creighton SM, Stanton SL. (1990). Caffeine: does it affect your bladder?. Br J Urol.
456 Crisp JC, Green NA, Ashken MH. (1976). Urodynamic studies in the district general hospital. Br J Urol.
457 Cronje HS, De Beer JA, Bam R. (2004). The pathophysiology of an enterocele and its management. J Obstet Gynaecol.
458 Crooks JE, Khan AB, Meddings RN, et al. (1995). Bladder transection revisited. Br J Urol.
459 Cross CA, Cespedes RD, English SF, et al. (1998). Transvaginal urethrolysis for urethral obstruction after anti-incontinence surgery. J Urol.
460 Cross CA, Cespedes RD, McGuire EJ. (1998). Our experience with pubovaginal slings in patients with stress urinary incontinence. J Urol.
461 Cucchi A. (1990). Acceleration of flow rate as a screening test for detrusor instability in women with stress incontinence. Br J Urol.
462 Cucchi A. (1993). Bladder contractility and idiopathic detrusor instability in the female. Br J Urol.
463 Cucchi A. (1998). A possible link between stress urinary incontinence and detrusor instability in the female--urodynamic (pressure/flow) data and speculative considerations. Int Urogynecol J Pelvic Floor Dysfunct.
464 Cucchi A. (1999). Sequential changes in voiding dynamics related to the development of detrusor instability in women with stress urinary incontinence. Neurourol Urodyn.
465 Cucchi A, Quaglini S, Siracusano S, et al. (2006). Urgency degree and bladder contraction velocity: sequential changes in women with idiopathic detrusor overactivity. Neurourol Urodyn.
466 Cucchi A, Siracusano S, Di Benedetto P, et al. (2004). Urgency of voiding and abdominal pressure transmission in women with mixed urinary incontinence. Neurourol Urodyn.
467 Cucchi A, Siracusano S, Guarnaschelli C, et al. (2003). Voiding urgency and detrusor contractility in women with overactive bladders. Neurourol Urodyn.
468 Cukier JM, Cortina-Borja M, Brading AF. (1997). A case-control study to examine any association between idiopathic detrusor instability and gastrointestinal tract disorder, and between irritable bowel syndrome and urinary tract disorder. Br J Urol.
469 Cundiff GW, Harris RL, Coates KW, et al. (1997). Clinical predictors of urinary incontinence in women. Am J Obstet Gynecol.
470 Curran MJ, Kaefer M, Peters C, et al. (2000). The overactive bladder in childhood: long-term results with conservative management. J Urol.
471 Currie CJ, McEwan P, Poole CD, et al. (2006). The impact of the overactive bladder on health-related utility and quality of life. BJU Int.
472 Dainer MJ, Zorn BH. (2000). Burch-Cooper’s ligament sling procedure: an augmented incontinence operation. Tech Urol.
473 Dallosso HM, McGrother CW, Matthews RJ, et al. (2003). The association of diet and other lifestyle factors with overactive bladder and stress incontinence: a longitudinal study in women. BJU Int.
474 Dalpiaz O, Primus G, Schips L. (2006). SPARC sling system for treatment of female stress urinary incontinence in the elderly. Eur Urol.
475 Darai E, Frobert JL, Grisard-Anaf M, et al. (2007). Functional results after the suburethral sling procedure for urinary stress incontinence: a prospective randomized multicentre study comparing the retropubic and transobturator routes. Eur Urol.
476 Darai E, Perdu M, Benifla JL, et al. (1997). Percutaneous needle colposuspension to Cooper’s ligament for the treatment of stress incontinence in women: a report of 82 cases. Eur J Obstet Gynecol Reprod Biol.
477 Darkow T, Fontes CL, Williamson TE. (2005). Costs associated with the management of overactive bladder and related comorbidities. Pharmacotherapy.
478 Darkow T, Fontes CL, Williamson TE, et al. (2005). Drug use issues and actions Non-elderly patients with overactive bladder have significant comorbidities. Formulary.
479 Darling R, Neilson D. (2005). Convenience voids: an important new factor in urinary frequency volume chart analysis. J Urol.
480 Das AK, Carlson AM, Hull M. (2004). Improvement in depression and health-related quality of life after sacral nerve stimulation therapy for treatment of voiding dysfunction. Urology.
481 Das S. (1999). Dynamic suburethral suspension with pedicled external oblique aponeurosis in the management of female urinary incontinence. J Urol.
482 Dattilo J. (2001). A long-term study of patient outcomes with pelvic muscle re-education for urinary incontinence. J Wound Ostomy Continence Nurs.
483 Davies MC, Crouch NS, Woodhouse CR, et al. (2005). Congenital adrenal hyperplasia and lower urinary tract symptoms. BJU Int.
484 Davila GW, Bernier F, Franco J, et al. (2003). Bladder dysfunction in sexual abuse survivors. J Urol.
485 Davis TL, Lukacz ES, Luber KM, et al. (2004). Determinants of patient satisfaction after the tension-free vaginal tape procedure. Am J Obstet Gynecol.
486 Day PL. (2000). Findings of a three-year retrospective study to investigate prevalence and incidence of urinary incontinence and overactive bladder in a typical managed care setting. Pharm Pract Manag Q.
487 de Araujo MP, Faria AC, Takano CC, et al. (2008). Urodynamic study and quality of life in patients with fibromyalgia and lower urinary tract symptoms. Int Urogynecol J Pelvic Floor Dysfunct.
488 De Bruin VS, Machado C, Howard RS, et al. (1996). Nocturnal and respiratory disturbances in Steele-Richardson-Olszewski syndrome (progressive supranuclear palsy). Postgrad Med J.
489 De Cuyper EM, Ismail R, Maher CF. (2008). Laparoscopic Burch colposuspension after failed sub-urethral tape procedures: a retrospective audit. Int Urogynecol J Pelvic Floor Dysfunct.
490 De Gennaro M, Capitanucci ML, Mastracci P, et al. (2004). Percutaneous tibial nerve neuromodulation is well tolerated in children and effective for treating refractory vesical dysfunction. J Urol.
491 de Kort LM, Nesselaar CH, van Gool JD, et al. (1997). The influence of colonic enema irrigation on urodynamic findings in patients with neurogenic bladder dysfunction. Br J Urol.
492 De Muylder X, Claes H, Neven P, et al. (1992). Usefulness of urodynamic investigations in female incontinence. Eur J Obstet Gynecol Reprod Biol.
493 De Paepe H, Hoebeke P, Renson C, et al. (1998). Pelvic-floor therapy in girls with recurrent urinary tract infections and dysfunctional voiding. Br J Urol.
494 De Ridder D, Chandiramani V, Dasgupta P, et al. (1997). Intravesical capsaicin as a treatment for refractory detrusor hyperreflexia: a dual center study with long-term followup. J Urol.
495 De Ridder D, Vermeulen C, Ketelaer P, et al. (1999). Pelvic floor rehabilitation in multiple sclerosis. Acta Neurol Belg.
496 de Seze M, Gallien P, Denys P, et al. (2006). Intravesical glucidic capsaicin versus glucidic solvent in neurogenic detrusor overactivity: a double blind controlled randomized study. Neurourol Urodyn.
497 de Seze M, Wiart L, Ferriere J, et al. (1999). Intravesical instillation of capsaicin in urology: A review of the literature. Eur Urol.
498 de Seze M, Wiart L, Joseph PA, et al. (1998). Capsaicin and neurogenic detrusor hyperreflexia: a double-blind placebo-controlled study in 20 patients with spinal cord lesions. Neurourol Urodyn.
499 de Tayrac R, Chevalier N, Chauveaud-Lambling A, et al. (2007). Is vaginal hysterectomy a risk factor for urinary incontinence at long-term follow-up?. Eur J Obstet Gynecol Reprod Biol.
500 De Wachter S, Vermandel A, De Moerloose K, et al. (2002). Value of increase in bladder capacity in treatment of refractory monosymptomatic nocturnal enuresis in children. Urology.
501 De Wachter S, Wyndaele JJ. (2008). How sudden is a compelling desire to void? An observational cystometric study on the suddenness of this sensation. BJU Int.
502 Deans CL, Morris AR, O’Sullivan R, et al. (2004). Voiding difficulty and other adverse events after tension free vaginal tape. Australian & New Zealand Continence Journal.
503 Debodinance P, Delporte P, Engrand JB, et al. (2002). Tension-free vaginal tape (TVT) in the treatment of urinary stress incontinence: 3 years experience involving 256 operations. Eur J Obstet Gynecol Reprod Biol.
504 Deffieux X, Hubeaux K, Porcher R, et al. (2008). Abnormal pelvic response to cough in women with stress urinary incontinence. Neurourol Urodyn.
505 Defreitas GA, Lemack GE, Zimmern PE, et al. (2003). Distinguishing neurogenic from non-neurogenic detrusor overactivity: a urodynamic assessment of lower urinary tract symptoms in patients with and without Parkinson’s disease. Urology.
506 del Campo-Rodriguez M, Batista-Miranda JE, Errando-Smet C, et al. (1999). Outcome of colposuspension in patients with stress urinary incontinence and abnormal cystometry. Arch Esp Urol.
507 Del Carro U, Riva D, Comi GC, et al. (1993). Neurophysiological evaluation in detrusor instability. Neurourol Urodyn.
508 Del Pizzo JJ, Chew BH, Jacobs SC, et al. (1998). Treatment of radiation induced hemorrhagic cystitis with hyperbaric oxygen: long-term followup. J Urol.
509 Delaere KP, Debruyne FM, Moonen WA. (1981). The use of indomethacin in the treatment of idiopathic bladder instability. Urol Int.
510 Delaere KP, Michiels HG, Debruyne FM, et al. (1977). Flavoxate hydrochloride in the treatment of detrusor instability. Urol Int.
511 Demain S, Smith JF, Hiller L, et al. (2001). Comparison of group and individual physiotherapy for female urinary incontinence in primary care: pilot study. Physiotherapy.
512 Demirci F, Yucel O. (2001). Comparison of pubovaginal sling and burch colposuspension procedures in type I/II genuine stress incontinence. Arch Gynecol Obstet.
513 Demirci F, Yucel O, Eren S, et al. (2001). Long-term results of Burch colposuspension. Gynecol Obstet Invest.
514 Dennis PJ, Rohner TJ, Hu TW, et al. (1991). Simple urodynamic evaluation of incontinent elderly female nursing home patients. A descriptive analysis. Urology.
515 Densmore M. (1982). Incontinence in the female patient. J Fam Pract.
516 Deutekom M, Dobben AC, Terra MP, et al. (2007). Clinical presentation of fecal incontinence and anorectal function: what is the relationship?. Am J Gastroenterol.
517 Deval B, Ferchaux J, Berry R, et al. (2006). Objective and subjective cure rates after trans-obturator tape (OBTAPE) treatment of female urinary incontinence. Eur Urol.
518 Deval B, Levardon M, Samain E, et al. (2003). A French multicenter clinical trial of SPARC for stress urinary incontinence. Eur Urol.
519 Di Rovasenda E, Podesta E, Scarsi P, et al. (1992). Treatment and follow-up of vesico-ureteral reflux in patients with neuropathic bladder. Eur J Pediatr Surg.
520 Diefenbach K, Arold G, Wollny A, et al. (2005). Effects on sleep of anticholinergics used for overactive bladder treatment in healthy volunteers aged > or = 50 years. BJU Int.
521 Diefenbach K, Jaeger K, Wollny A, et al. (2008). Effect of tolterodine on sleep structure modulated by CYP2D6 genotype. Sleep Med.
522 Dietz HP, Barry C, Lim YN, et al. (2005). Two-dimensional and three-dimensional ultrasound imaging of suburethral slings. Ultrasound Obstet Gynecol.
523 Dietz HP, Barry C, Rane A, et al. (2006). Is the cough test necessary at TVT insertion? A case control series Tension-free vaginal tape (TVT). Australian & New Zealand Continence Journal.
524 Dietz HP, Clarke B. (2001). Is the irritable bladder associated with anterior compartment relaxation? A critical look at the ‘integral theory of pelvic floor dysfunction’. Aust N Z J Obstet Gynaecol.
525 Dietz HP, Foote AJ, Mak HL, et al. (2004). TVT and Sparc suburethral slings: a case-control series. Int Urogynecol J Pelvic Floor Dysfunct.
526 Dietz HP, Mouritsen L, Ellis G, et al. (2004). How important is TVT location?. Acta Obstet Gynecol Scand.
527 Dietz HP, Simpson JM. (2008). Levator trauma is associated with pelvic organ prolapse. BJOG.
528 Dietz HP, Wilson PD. (2000). Colposuspension success and failure: a long-term objective follow-up study. Int Urogynecol J Pelvic Floor Dysfunct.
529 Dietz HP, Wilson PD. (2005). Laparoscopic colposuspension versus urethropexy: a case-control series. Int Urogynecol J Pelvic Floor Dysfunct.
530 Dietz HP, Wilson PD, Clarke B, et al. (2001). Irritative symptoms after colposuspension: are they due to distortion or overelevation of the anterior vaginal wall and trigone?. Int Urogynecol J Pelvic Floor Dysfunct.
531 Digesu GA, Athanasiou S, Chaliha C, et al. (2006). Urethral retro-resistance pressure and urodynamic diagnoses in women with lower urinary tract symptoms. BJOG.
532 Digesu GA, Chaliha C, Khullar V, et al. (2007). The relationship of urethral resistance pressure and pressure flow parameters in women with lower urinary tract symptoms. Int Urogynecol J Pelvic Floor Dysfunct.
533 Digesu GA, Hutchings A, Salvatore S, et al. (2004). Pressure flow study: a useful diagnostic test of female lower urinary tract symptoms. Neurourol Urodyn.
534 Digesu GA, Khullar V, Cardozo L, et al. (2003). Overactive bladder symptoms: do we need urodynamics?. Neurourol Urodyn.
535 Digesu GA, Khullar V, Cardozo L, et al. (2004). The open bladder neck: a significant finding?. Int Urogynecol J Pelvic Floor Dysfunct.
536 Digesu GA, Khullar V, Cardozo L, et al. (2004). Preoperative pressure-flow studies: useful variables to predict the outcome of continence surgery. BJU Int.
537 Digesu GA, Khullar V, Panayi D, et al. (2008). Should we explain lower urinary tract symptoms to patients?. Neurourol Urodyn.
538 Digesu GA, Salvatore S, Chaliha C, et al. (2007). Do overactive bladder symptoms improve after repair of anterior vaginal wall prolapse?. Int Urogynecol J Pelvic Floor Dysfunct.
539 Digesu GA, Salvatore S, Fernando R, et al. (2008). Mixed urinary symptoms: what are the urodynamic findings?. Neurourol Urodyn.
540 Diggs C, Meyer WA, Langenberg P, et al. (2007). Assessing urgency in interstitial cystitis/painful bladder syndrome. Urology.
541 Dik P, Klijn AJ, van Gool JD, et al. (2006). Early start to therapy preserves kidney function in spina bifida patients. Eur Urol.
542 Diokno AC, Catipay JR, Steinert BW. (2002). Office assessment of patient outcome of pharmacologic therapy for urge incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
543 Diokno AC, Homma Y, Sekiguchi Y, et al. (2003). Interstitial cystitis, gynecologic pelvic pain, prostatitis, and their epidemiology. Int J Urol.
544 Diokno AC, Sand PK, Macdiarmid S, et al. (2006). Perceptions and behaviours of women with bladder control problems. Fam Pract.
545 Diokno AC, Vinson RK, McGillicuddy J. (1977). Treatment of the severe uninhibited neurogenic bladder by selective sacral rhizotomy. J Urol.
546 Diokno AC, Wells TJ, Brink CA. (1987). Urinary incontinence in elderly women: urodynamic evaluation. J Am Geriatr Soc.
547 Dmochowski R. (2005). Urinary frequency: event measure, outcome significance?. Curr Urol Rep.
548 Dmochowski R, Abrams P, Marschall-Kehrel D, et al. (2007). Efficacy and tolerability of tolterodine extended release in male and female patients with overactive bladder. Eur Urol.
549 Dmochowski RR. (2002). Management of postoperative overactive bladder complications. Geriatrics.
550 Dmochowski RR, Avon M, Ross J, et al. (2003). Transvaginal radio frequency treatment of the endopelvic fascia: a prospective evaluation for the treatment of genuine stress urinary incontinence. J Urol.
551 Dmochowski RR, Miklos JR, Norton PA, et al. (2003). Duloxetine versus placebo for the treatment of North American women with stress urinary incontinence. J Urol.
552 Dmochowski RR, Newman DK. (2007). Impact of overactive bladder on women in the United States: results of a national survey. Curr Med Res Opin.
553 Dmochowski RR, Nitti V, Staskin D, et al. (2005). Transdermal oxybutynin in the treatment of adults with overactive bladder: combined results of two randomized clinical trials. World J Urol.
554 Dockter M, Kolstad AM, Martin KA, et al. (2007). Prevalence of urinary incontinence: a comparative study of collegiate femaleathletes [sic] and non-athletic controls. Journal of Women’s Health Physical Therapy.
555 Domingo S, Alama P, Ruiz N, et al. (2007). Transobturator tape procedure outcome: a clinical and quality of life analysis of a 1-year follow-up. Int Urogynecol J Pelvic Floor Dysfunct.
556 Dong D, Xu Z, Shi B, et al. (2006). Urodynamic study in the neurogenic bladder dysfunction caused by intervertebral disk hernia. Neurourol Urodyn.
557 Doo CK, Hong B, Chung BJ, et al. (2006). Five-year outcomes of the tension-free vaginal tape procedure for treatment of female stress urinary incontinence. Eur Urol.
558 Dooley Y, Lowenstein L, Kenton K, et al. (2008). Mixed incontinence is more bothersome than pure incontinence subtypes. Int Urogynecol J Pelvic Floor Dysfunct.
559 Dorflinger A, Gorton E, Stanton S, et al. (2002). Urethral pressure profile: is it affected by position?. Neurourol Urodyn.
560 Dorschner W, Stolzenburg JU, Griebenow R, et al. (2000). Efficacy and cardiac safety of propiverine in elderly patients - a double-blind, placebo-controlled clinical study. Eur Urol.
561 Dowd T, Kolcaba K, Steiner R. (2002). Correlations among measures of bladder function and comfort. J Nurs Meas.
562 Drake MJ, Gardner BP, Brading AF. (2003). Innervation of the detrusor muscle bundle in neurogenic detrusor overactivity. BJU Int.
563 Drake MJ, Harvey IJ, Gillespie JI, et al. (2005). Localized contractions in the normal human bladder and in urinary urgency. BJU Int.
564 Drake MJ, Hedlund P, Andersson KE, et al. (2003). Morphology, phenotype and ultrastructure of fibroblastic cells from normal and neuropathic human detrusor: absence of myofibroblast characteristics. J Urol.
565 Drake NL, Flynn MK, Romero AA, et al. (2005). Nocturnal polyuria in women with overactive bladder symptoms and nocturia. Am J Obstet Gynecol.
566 Dryden MS, Wilkinson M, Redman M, et al. (1994). Detection of Chlamydia trachomatis in general practice urine samples. Br J Gen Pract.
567 D’Souza AO, Smith MJ, Miller LA, et al. (2008). Persistence, adherence, and switch rates among extended-release and immediate-release overactive bladder medications in a regional managed care plan. J Manag Care Pharm.
568 DuBeau CE. (2001). Urinary incontinence. Clinical Geriatrics.
569 DuBeau CE, Bent AE, Dmochowski RR, et al. (2003). Addressing the unmet needs of geriatric patients with overactive bladder: challenges and controversies. Clinical Geriatrics.
570 DuBeau CE, Khullar V, Versi E. (2005). “Unblinding” in randomized controlled drug trials for urinary incontinence: Implications for assessing outcomes when adverse effects are evident. Neurourol Urodyn.
571 DuBeau CE, Kiely DK, Resnick NM. (1999). Quality of life impact of urge incontinence in older persons: a new measure and conceptual structure. J Am Geriatr Soc.
572 DuBeau CE, Levy B, Mangione CM, et al. (1998). The impact of urge urinary incontinence on quality of life: importance of patients’ perspective and explanatory style. J Am Geriatr Soc.
573 Duckett J, Aggarwal I, Basu M, et al. (2007). The value of cystoscopy and bladder biopsy taken at the time of tension-free vaginal tape insertion. J Obstet Gynaecol.
574 Duckett J, Aggarwal I, Patil A, et al. (2008). Effect of tension-free vaginal tape position on the resolution of irritative bladder symptoms in women with mixed incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
575 Duckett JR, Basu M. (2007). The predictive value of preoperative pressure-flow studies in the resolution of detrusor overactivity and overactive bladder after tension-free vaginal tape insertion. BJU Int.
576 Duckett JR, Tamilselvi A. (2006). Effect of tension-free vaginal tape in women with a urodynamic diagnosis of idiopathic detrusor overactivity and stress incontinence. BJOG.
577 Duckett JR, Vella M, Kavalakuntla G, et al. (2007). Tolerability and efficacy of duloxetine in a nontrial situation. BJOG.
578 Duldulao KE, Diokno AC, Mitchell B. (1997). Value of urinary cytology in women presenting with urge incontinence and/or irritative voiding symptoms. J Urol.
579 Dunn M, Smith JC, Ardran GM. (1974). Prolonged bladder distension as a treatment of urgency and urge incontinence of urine. Br J Urol.
580 Dunn MD, Portis AJ, Kahn SA, et al. (2000). Clinical effectiveness of new stent design: randomized single-blind comparison of tail and double-pigtail stents. J Endourol.
581 Durufle A, Petrilli S, Nicolas B, et al. (2006). Effects of pregnancy and child birth on urinary symptoms and urodynamics in women with multiple sclerosis. Int Urogynecol J Pelvic Floor Dysfunct.
582 Dwyer PL, Desmedt E. (1994). Impaired bladder emptying in women. Aust N Z J Obstet Gynaecol.
583 Dwyer PL, Lee ET, Hay DM. (1988). Obesity and urinary incontinence in women. Br J Obstet Gynaecol.
584 Dykstra D, Enriquez A, Valley M. (2003). Treatment of overactive bladder with botulinum toxin type B: a pilot study. Int Urogynecol J Pelvic Floor Dysfunct.
585 Eastwood HD, Warrell R. (1984). Urinary incontinence in the elderly female: prediction in diagnosis and outcome of management. Age Ageing.
586 Eckford SD, Swami KS, Jackson SR, et al. (1994). Desmopressin in the treatment of nocturia and enuresis in patients with multiple sclerosis. Br J Urol.
587 Edlund C, Dijkema HE, Hassouna MM, et al. (2004). Sacral nerve stimulation for refractory urge symptoms in elderly patients. Scand J Urol Nephrol.
588 Edlund C, Hellstrom M, Peeker R, et al. (2000). First Scandinavian experience of electrical sacral nerve stimulation in the treatment of the overactive bladder. Scand J Urol Nephrol.
589 Edlund C, Peeker R, Fall M. (2001). Clam ileocystoplasty: successful treatment of severe bladder overactivity. Scand J Urol Nephrol.
590 Edlund C, Peeker R, Fall M. (2001). Lidocaine cystometry in the diagnosis of bladder overactivity. Neurourol Urodyn.
591 Ehren I, Hosseini A, Lundberg JO, et al. (1999). Nitric oxide: a useful gas in the detection of lower urinary tract inflammation. J Urol.
592 Ehren I, Volz D, Farrelly E, et al. (2007). Efficacy and impact of botulinum toxin A on quality of life in patients with neurogenic detrusor overactivity: a randomised, placebo-controlled, double-blind study. Scand J Urol Nephrol.
593 Eiberg H, Shaumburg HL, Von Gontard A, et al. (2001). Linkage study of a large Danish 4-generation family with urge incontinence and nocturnal enuresis. J Urol.
594 Ekman G, Andersson KE, Rud T, et al. (1980). A double-blind, cross-over study of the effects of terodiline in women with unstable bladder. Acta Pharmacol Toxicol (Copenh).
595 Ekstrom A, Altman D, Wiklund I, et al. (2008). Planned cesarean section versus planned vaginal delivery: comparison of lower urinary tract symptoms. Int Urogynecol J Pelvic Floor Dysfunct.
596 Ekstrom B, Andersson KE, Mattiasson A. (1993). Urodynamic effects of intravesical instillation of atropine and phentolamine in patients with detrusor hyperactivity. J Urol.
597 Elbadawi A, Hailemariam S, Yalla SV, et al. (1997). Structural basis of geriatric voiding dysfunction. VI. Validation and update of diagnostic criteria in 71 detrusor biopsies. J Urol.
598 Elbadawi A, Hailemariam S, Yalla SV, et al. (1997). Structural basis of geriatric voiding dysfunction. VII. Prospective ultrastructural/urodynamic evaluation of its natural evolution. J Urol.
599 Elbadawi A, Resnick NM, Dorsam J, et al. (2003). Structural basis of neurogenic bladder dysfunction. I. Methods of prospective ultrastructural study and overview of the findings. J Urol.
600 Elbadawi A, Yalla SV, Resnick NM. (1993). Structural basis of geriatric voiding dysfunction. I. Methods of a prospective ultrastructural/urodynamic study and an overview of the findings. J Urol.
601 Elbadawi A, Yalla SV, Resnick NM. (1993). Structural basis of geriatric voiding dysfunction. II. Aging detrusor: normal versus impaired contractility. J Urol.
602 Elbadawi A, Yalla SV, Resnick NM. (1993). Structural basis of geriatric voiding dysfunction. III. Detrusor overactivity. J Urol.
603 Elbadawi A, Yalla SV, Resnick NM. (1993). Structural basis of geriatric voiding dysfunction. IV. Bladder outlet obstruction. J Urol.
604 Elder DD, Stephenson TP. (1980). An assessment of the Frewen regime in the treatment of detrusor dysfunction in females. Br J Urol.
605 Elder DD, Stephenson TP, Bary PR. (1981). An assessment of the Frewen regime in the treatment of detrusor dysfunction in females. Prog Clin Biol Res.
606 Elder JS. (1997). Bladder rehabilitation, the effect of a cognitive training programme on urge incontinence. J Urol.
607 Elder JS, Snyder HM, Peters C, et al. (1992). Variations in practice among urologists and nephrologists treating children with vesicoureteral reflux. J Urol.
608 Elem B, Patil PS, Lucas SB. (1991). Haematuria frequency syndrome in patients with positive HIV serology: observations in Zambia. Br J Urol.
609 Elgamasy AN, Lewis V, Hassouna ME, et al. (1996). Effect of transvaginal stimulation in the treatment of detrusor instability. Urol Nurs.
610 Elhilali MM, Khaled SM, Kashiwabara T, et al. (2005). Sacral neuromodulation: long-term experience of one center. Urology.
611 Elkins TE, Ghosh TS, Tagoe GA, et al. (1992). Transvaginal mobilization and utilization of the anterior bladder wall to repair vesicovaginal fistulas involving the urethra. Obstet Gynecol.
612 Elliott RA, Norman RI, Parker SG, et al. (1996). Effect of treatment with calcium antagonists in vitro and in vivo on the contractile response of isolated rat and human detrusor muscle. Clin Sci (Lond).
613 Ellsworth PI, Borgstein NG, Nijman RJ, et al. (2005). Use of tolterodine in children with neurogenic detrusor overactivity: relationship between dose and urodynamic response. J Urol.
614 El-Nahas AR, El-Assmy AM, Shoma AM, et al. (2006). Self-retaining ureteral stents: analysis of factors responsible for patients’ discomfort. J Endourol.
615 Elser DM, Wyman JF, McClish DK, et al. (1999). The effect of bladder training, pelvic floor muscle training, or combination training on urodynamic parameters in women with urinary incontinence. Continence Program for Women Research Group. Neurourol Urodyn.
616 el-Toukhy TA, Davies AE. (2001). The efficacy of laparoscopic mesh colposuspension: results of a prospective controlled study. BJU Int.
617 Elzevier HW, Venema PL, Lycklama a Nijeholt AA. (2004). Sexual function after tension-free vaginal tape (TVT) for stress incontinence: results of a mailed questionnaire. Int Urogynecol J Pelvic Floor Dysfunct.
618 Engel AF, Kamm MA, Bartram CI, et al. (1995). Relationship of symptoms in faecal incontinence to specific sphincter abnormalities. Int J Colorectal Dis.
619 English PJ, Fowler JW. (1988). Videourodynamic assessment of the Stamey procedure for stress incontinence. Br J Urol.
620 Erdogru T, Kocak T, Serdaroglu P, et al. (1999). Evaluation and therapeutic approaches of voiding and erectile dysfunction in neurological Behcet’s syndrome. J Urol.
621 Eregie CO. (1998). Observations on urinary frequency in exclusively breastfed neonates. East Afr Med J.
622 Eriksen BC, Bergmann S, Mjolnerod OK. (1987). Effect of anal electrostimulation with the ‘Incontan’ device in women with urinary incontinence. Br J Obstet Gynaecol.
623 Eriksen BC, Hagen B, Eik-Nes SH, et al. (1990). Long-term effectiveness of the Burch colposuspension in female urinary stress incontinence. Acta Obstet Gynecol Scand.
624 Eriksen BC, Mjolnerod OK. (1987). Changes in urodynamic measurements after successful anal electrostimulation in female urinary incontinence. Br J Urol.
625 Ertberg P, Moller LA, Lose G. (2003). A comparison of three methods to evaluate maximum bladder capacity: cystometry, uroflowmetry and a 24-h voiding diary in women with urinary incontinence. Acta Obstet Gynecol Scand.
626 Esa A, Kiwamoto H, Sugiyama T, et al. (1991). Functional electrical stimulation in the management of incontinence: studies of urodynamics. Int Urol Nephrol.
627 Espuna Pons M, Puig Clota M. (2008). Coital urinary incontinence: impact on quality of life as measured by the King’s Health Questionnaire. Int Urogynecol J Pelvic Floor Dysfunct.
628 Espuna-Pons M, Dilla T, Castro D, et al. (2007). Analysis of the value of the ICIQ-UI SF questionnaire and stress test in the differential diagnosis of the type of urinary incontinence. Neurourol Urodyn.
629 Essenhigh DM, Ryan DW. (1982). An appraisal of S3 blocks in the management of incontinence. Br J Urol.
630 Esteghamati A, Rashidi A, Nikfallah A, et al. (2007). The association between urodynamic findings and microvascular complications in patients with long-term type 2 diabetes but without voiding symptoms. Diabetes Res Clin Pract.
631 Ethans KD, Nance PW, Bard RJ, et al. (2004). Efficacy and safety of tolterodine in people with neurogenic detrusor overactivity. J Spinal Cord Med.
632 Everaert K, De Ridder D, Baert L, et al. (2000). Patient satisfaction and complications following sacral nerve stimulation for urinary retention, urge incontinence and perineal pain: a multicenter evaluation. Int Urogynecol J Pelvic Floor Dysfunct.
633 Ewing R, Bultitude MI, Shuttleworth KE. (1982). Subtrigonal phenol injection for urge incontinence secondary to detrusor instability in females. Br J Urol.
634 Ewing R, Bultitude MI, Shuttleworth KE. (1983). Subtrigonal phenol injection therapy for incontinence in female patients with multiple sclerosis. Lancet.
635 Ezzat IM. (2003). Sling operations in the treatment of stress urinary incontinence: how to adjust sling tension. J Obstet Gynaecol Res.
636 Faber P, Heidenreich J. (1977). Effect of intravenous butylscopolamine infusion on urge incontinence. Urol Int.
637 Faerber GJ. (1998). Urethral diverticulectomy and pubovaginal sling for simultaneous treatment of urethral diverticulum and intrinsic sphincter deficiency. Tech Urol.
638 Fall M. (1984). Does electrostimulation cure urinary incontinence?. J Urol.
639 Fall M. (1985). Conservative management of chronic interstitial cystitis: transcutaneous electrical nerve stimulation and transurethral resection. J Urol.
640 Fall M, Ahlstrom K, Carlsson CA, et al. (1986). Contelle: pelvic floor stimulator for female stress-urge incontinence. A multicenter study. Urology.
641 Fall M, Erlandson BE, Carlsson CA, et al. (1978). Effects of electrical intravaginal stimulation on bladder volume: an experimental and clinical study. Urol Int.
642 Fall M, Erlandson BE, Nilson AE, et al. (1977). Long-term intravaginal electrical stimulation in urge and stress incontinence. Scand J Urol Nephrol Suppl.
643 Fall M, Erlandson BE, Pettersson S. (1984). Evaluation of history and simple supine cystometry as a preoperative test in stress urinary incontinence. Acta Obstet Gynecol Scand.
644 Fall M, Erlandson BE, Sundin T, et al. (1977). Intravaginal electrical stimulation. Clinical experiments on bladder inhibition. Scand J Urol Nephrol Suppl.
645 Fall M, Ohlsson BL, Carlsson CA. (1989). The neurogenic overactive bladder. Classification based on urodynamics. Br J Urol.
646 Fall M, Pettersson S. (1983). The simplified Lapides’ operation for stress incontinence. Scand J Urol Nephrol.
647 Fantl JA. (1998). Behavioral intervention for community-dwelling individuals with urinary incontinence. Urology.
648 Fantl JA, Bump RC, Robinson D, et al. (1996). Efficacy of estrogen supplementation in the treatment of urinary incontinence. The Continence Program for Women Research Group. Obstet Gynecol.
649 Fantl JA, Harkins SW, Wyman JF, et al. (1987). Fluid loss quantitation test in women with urinary incontinence: a test-retest analysis. Obstet Gynecol.
650 Fantl JA, Hurt WG, Beachley MC, et al. (1981). Bead-chain cystourethrogram: an evaluation. Obstet Gynecol.
651 Fantl JA, Wyman JF, Anderson RL, et al. (1988). Postmenopausal urinary incontinence: comparison between non-estrogen-supplemented and estrogen-supplemented women. Obstet Gynecol.
652 Fantl JA, Wyman JF, McClish DK, et al. (1990). Urinary incontinence in community-dwelling women: clinical, urodynamic, and severity characteristics. Am J Obstet Gynecol.
653 Fantl JA, Wyman JF, McClish DK, et al. (1991). Efficacy of bladder training in older women with urinary incontinence. JAMA.
654 Farghaly SA, Hindmarsh JR, Worth PH. (1986). Post-hysterectomy urethral dysfunction: evaluation and management. Br J Urol.
655 Farrar DJ, Osborne JL. (1976). The use of bromocriptine in the treatment of the unstable bladder. Br J Urol.
656 Farrell SA, Baydock S, Amir B, et al. (2007). Effectiveness of a new self-positioning pessary for the management of urinary incontinence in women. Am J Obstet Gynecol.
657 Farrell SA, Singh B, Aldakhil L. (2004). Continence pessaries in the management of urinary incontinence in women. J Obstet Gynaecol Can.
658 Farrell SA, Tynski G. (1996). The effect of urethral pressure variation on detrusor activity in women. Int Urogynecol J Pelvic Floor Dysfunct.
659 Fehrling M, Fall M, Peeker R. (2007). Maximal functional electrical stimulation as a single treatment: is it cost-effective?. Scand J Urol Nephrol.
660 Fehrmann-Zumpe P, Karbe K, Blessman G. (1999). Using flavoxate as primary medication for patients suffering from urge symptomatology. Int Urogynecol J Pelvic Floor Dysfunct.
661 Felsen D, Frye S, Trimble LA, et al. (1994). Inflammatory mediator profile in urine and bladder wash fluid of patients with interstitial cystitis. J Urol.
662 Fernando RJ, Thakar R, Sultan AH, et al. (2006). Effect of vaginal pessaries on symptoms associated with pelvic organ prolapse. Obstet Gynecol.
663 Fernie GR, Jewett MA, Halsall P, et al. (1983). Urodynamic characterization of incontinence in the elderly by bladder volume. J Urol.
664 Ferrara P, Costa S, Rigante D, et al. (2003). Intramedullary epidermoid cyst presenting with abnormal urological manifestations. Spinal Cord.
665 Ferrara P, Rigante D, D’Aleo C, et al. (2006). Preliminary data on monosymptomatic nocturnal enuresis in children and adolescents with type 1 diabetes. Scand J Urol Nephrol.
666 Ferrie BG, Smith JS, Logan D, et al. (1984). Experience with bladder training in 65 patients. Br J Urol.
667 Fielding JR, Lee JH, Dubeau CE, et al. (2000). Voiding cystourethrography findings in elderly women with urge incontinence. J Urol.
668 Fieler VK. (1997). Side effects and quality of life in patients receiving high-dose rate brachytherapy. Oncol Nurs Forum.
669 Fihn SD, Johnson C, Roberts PL, et al. (1988). Trimethoprim-sulfamethoxazole for acute dysuria in women: a single-dose or 10-day course. A double-blind, randomized trial. Ann Intern Med.
670 Finazzi Agro E, Campagna A, Sciobica F, et al. (2005). Posterior tibial nerve stimulation: is the once-a-week protocol the best option?. Minerva Urol Nefrol.
671 Fine PM, Mauldin JE, Harte EH. (1988). Stress incontinence in women. A practical method of evaluation. J Reprod Med.
672 Fink D, Perucchini D, Schaer GN, et al. (1999). The role of the frequency-volume chart in the differential diagnostic of female urinary incontinence. Acta Obstet Gynecol Scand.
673 Finkelstein K, Glosner S, Sanchez RJ, et al. (2008). Prevalence of probable overactive bladder in a private obstetrics and gynecology group practice. Curr Med Res Opin.
674 Finnerty P. (2006). Overactive bladder. World of Irish Nursing & Midwifery.
675 Fischer W, Linde A. (1997). Pelvic floor findings in urinary incontinence--results of conditioning using vaginal cones. Acta Obstet Gynecol Scand.
676 Fischer-Rasmussen W. (1984). Evaluation of long-term safety and clinical benefit of terodiline in women with urgency/urge incontinence. A multicentre study. Scand J Urol Nephrol Suppl.
677 Fischer-Rasmussen W. (1998). Transvaginal needle bladder neck suspension for stress urinary incontinence: practicable methods but not optimal results. Acta Obstet Gynecol Scand Suppl.
678 Fischer-Rasmussen W, Hansen RI, Stage P. (1986). Predictive values of diagnostic tests in the evaluation of female urinary stress incontinence. Acta Obstet Gynecol Scand.
679 Fitzgerald MP, Ayuste D, Brubaker L. (2005). How do urinary diaries of women with an overactive bladder differ from those of asymptomatic controls?. BJU Int.
680 FitzGerald MP, Brubaker L. (2002). Urinary incontinence symptom scores and urodynamic diagnoses. Neurourol Urodyn.
681 Fitzgerald MP, Brubaker L. (2003). Variability of 24-hour voiding diary variables among asymptomatic women. J Urol.
682 FitzGerald MP, Butler N, Shott S, et al. (2002). Bother arising from urinary frequency in women. Neurourol Urodyn.
683 Fitzgerald MP, Jaffar J, Brubaker L. (2001). Risk factors for an elevated postvoid residual urine volume in women with symptoms of urinary urgency, frequency and urge incontience. Int Urogynecol J Pelvic Floor Dysfunct.
684 FitzGerald MP, Kenton KS, Brubaker L. (2005). Localization of the urge to void in patients with painful bladder syndrome. Neurourol Urodyn.
685 FitzGerald MP, Manaves V, Martin AF, et al. (2001). Myosin isoforms in female human detrusor. Neurourol Urodyn.
686 Fjorback MV, Rijkhoff N, Petersen T, et al. (2006). Event driven electrical stimulation of the dorsal penile/clitoral nerve for management of neurogenic detrusor overactivity in multiple sclerosis. Neurourol Urodyn.
687 Fjorback MV, Van Rey FS, Rijkhoff NJ, et al. (2007). Electrical stimulation of sacral dermatomes in multiple sclerosis patients with neurogenic detrusor overactivity. Neurourol Urodyn.
688 Fjorback MV, van Rey FS, van der Pal F, et al. (2007). Acute urodynamic effects of posterior tibial nerve stimulation on neurogenic detrusor overactivity in patients with MS. Eur Urol.
689 Fletcher S. (1988). Interstitial cystitis: painful bladder syndrome. Nurse Pract.
690 Fletcher SG, Lemack GE. (2008). Clarifying the role of urodynamics in the preoperative evaluation of stress urinary incontinence. ScientificWorldJournal.
691 Fliegner JR, Glenning PP. (1979). Seven years experience in the evaluation and management of patients with urge incontinence of urine. Aust N Z J Obstet Gynaecol.
692 Flisser AJ, Blaivas JG. (2002). Role of cystometry in evaluating patients with overactive bladder. Urology.
693 Flood HD, Malhotra SJ, O’Connell HE, et al. (1995). Long-term results and complications using augmentation cystoplasty in reconstructive urology. Neurourol Urodyn.
694 Flynn BJ, Yap WT. (2002). Pubovaginal sling using allograft fascia lata versus autograft fascia for all types of stress urinary incontinence: 2-year minimum followup. J Urol.
695 Flynn L, Cell P, Luisi E. (1994). Effectiveness of pelvic muscle exercises in reducing urge incontinence among community residing elders. J Gerontol Nurs.
696 Fonda D, Brimage PJ, D’Astoli M. (1993). Simple screening for urinary incontinence in the elderly: comparison of simple and multichannel cystometry. Urology.
697 Foote J, Glavind K, Kralidis G, et al. (2005). Treatment of overactive bladder in the older patient: pooled analysis of three phase III studies of darifenacin, an M3 selective receptor antagonist. Eur Urol.
698 Forman A, Andersson KE, Henriksson L, et al. (1978). Effects of nifedipine on the smooth muscle of the human urinary tract in vitro and in vivo. Acta Pharmacol Toxicol (Copenh).
699 Fortunato P, Schettini M, Gallucci M. (1997). Diverticula of the female urethra. Br J Urol.
700 Fossberg E, Beisland HO, Sander S. (1981). Sensory urgency in females: treatment with phenylpropanolamine. Eur Urol.
701 Foster MC, O’Reilly PH. (1989). Early experience of the gittes “no-incision” pubovaginal suspension for stress urinary incontinence. Br J Urol.
702 Foster RT, Anoia EJ, Webster GD, et al. (2007). In patients undergoing neuromodulation for intractable urge incontinence a reduction in 24-hr pad weight after the initial test stimulation best predicts long-term patient satisfaction. Neurourol Urodyn.
703 Foster RT, Barber MD, Parasio MF, et al. (2007). A prospective assessment of overactive bladder symptoms in a cohort of elderly women who underwent transvaginal surgery for advanced pelvic organ prolapse. Am J Obstet Gynecol.
704 Fowler CJ, Beck RO, Gerrard S, et al. (1994). Intravesical capsaicin for treatment of detrusor hyperreflexia. J Neurol Neurosurg Psychiatry.
705 Fox SD, Stanton SL. (2000). Vault prolapse and rectocele: assessment of repair using sacrocolpopexy with mesh interposition. BJOG.
706 Franco I, Landau-Dyer L, Isom-Batz G, et al. (2007). The use of botulinum toxin A injection for the management of external sphincter dyssynergia in neurologically normal children. J Urol.
707 Franco N, Shobeiri SA, Echols KT. (2002). Medium-term follow-up of transvaginal suburethral slings: variance in outcome success using two different evaluation methods. Urology.
708 Frauscher F, Helweg G, Strasser H, et al. (1998). Intraurethral ultrasound: diagnostic evaluation of the striated urethral sphincter in incontinent females. Eur Radiol.
709 Frazer MI, Haylen BT. (1989). Trigonal sensitivity testing in women. J Urol.
710 Frederick RW, Leach GE. (2005). Cadaveric prolapse repair with sling: intermediate outcomes with 6 months to 5 years of followup. J Urol.
711 Freeman RM. (2000). Female urinary incontinence: aetiology and pathophysiology. Hosp Med.
712 Freeman RM, Adekanmi O, Waterfield MR, et al. (2006). The effect of cannabis on urge incontinence in patients with multiple sclerosis: a multicentre, randomised placebo-controlled trial (CAMS-LUTS). Int Urogynecol J Pelvic Floor Dysfunct.
713 Freeman RM, McPherson FM, Baxby K. (1985). Psychological features of women with idiopathic detrusor instability. Urol Int.
714 Freiha FS, Faysal MH, Stamey TA. (1980). The surgical treatment of intractable interstitial cystitis. J Urol.
715 Frenkl TL, Rackley RR, Vasavada SP, et al. (2008). Management of iatrogenic foreign bodies of the bladder and urethra following pelvic floor surgery. Neurourol Urodyn.
716 Frewen WK. (1978). An objective assessment of the unstable bladder of psychosomatic origin. Br J Urol.
717 Frewen WK. (1980). The management of urgency and frequency of micturition. Br J Urol.
718 Frigerio L, Ferrari A, Candiani GB. (1981). The significance of the stop test in female urinary incontinence. Diagn Gynecol Obstet.
719 Friis E, Hjortrup A, Nielsen JE, et al. (1982). Urinary incontinence and genital prolapse: a prospective blind study of the value of urodynamic evaluation. J Urol.
720 Fritel X, Zabak K, Pigne A, et al. (2002). Predictive value of urethral mobility before suburethral tape procedure for urinary stress incontinence in women. J Urol.
721 Frohlich G, Bulitta M, Strosser W. (2002). Trospium chloride in patients with detrusor overactivity: meta-analysis of placebo-controlled, randomized, double-blind, multi-center clinical trials on the efficacy and safety of 20 mg trospium chloride twice daily. Int J Clin Pharmacol Ther.
722 Fujishiro T, Takahashi S, Enomoto H, et al. (2002). Magnetic stimulation of the sacral roots for the treatment of urinary frequency and urge incontinence: an investigational study and placebo controlled trial. J Urol.
723 Fulford SC, Flynn R, Barrington J, et al. (1999). An assessment of the surgical outcome and urodynamic effects of the pubovaginal sling for stress incontinence and the associated urge syndrome. J Urol.
724 Fulmer BR, Sakamoto K, Turk TM, et al. (2002). Acute and long-term outcomes of radio frequency bladder neck suspension. J Urol.
725 Gajewski JB, Awad SA. (1986). Oxybutynin versus propantheline in patients with multiple sclerosis and detrusor hyperreflexia. J Urol.
726 Galejs LE, Diokno AC. (1998). Frequency urgency syndrome following urinary bladder suspension. Geriatr Nephrol Urol.
727 Galloway NT, El-Galley RE, Sand PK, et al. (1999). Extracorporeal magnetic innervation therapy for stress urinary incontinence. Urology.
728 Galloway NT, El-Galley RE, Sand PK, et al. (2000). Update on extracorporeal magnetic innervation (EXMI) therapy for stress urinary incontinence. Urology.
729 Gamble TL, Botros SM, Beaumont JL, et al. (2008). Predictors of persistent detrusor overactivity after transvaginal sling procedures. Am J Obstet Gynecol.
730 Game X, Castel-Lacanal E, Bentaleb Y, et al. (2008). Botulinum toxin A detrusor injections in patients with neurogenic detrusor overactivity significantly decrease the incidence of symptomatic urinary tract infections. Eur Urol.
731 Gandini R, Chiocchi M, Konda D, et al. (2008). Transcatheter foam sclerotherapy of symptomatic female varicocele with sodium-tetradecyl-sulfate foam. Cardiovasc Intervent Radiol.
732 Ganesan T, Khadra MH, Wallis J, et al. (2002). Vitamin B12 malabsorption following bladder reconstruction or diversion with bowel segments. ANZ J Surg.
733 Ganio E, Luc AR, Clerico G, et al. (2001). Sacral nerve stimulation for treatment of fecal incontinence: a novel approach for intractable fecal incontinence. Dis Colon Rectum.
734 Ganio E, Masin A, Ratto C, et al. (2001). Short-term sacral nerve stimulation for functional anorectal and urinary disturbances: results in 40 patients: evaluation of a new option for anorectal functional disorders. Dis Colon Rectum.
735 Gardy M, Kozminski M, DeLancey J, et al. (1991). Stress incontinence and cystoceles. J Urol.
736 Garnick MB, Schade D, Israel M, et al. (1984). Intravesical doxorubicin for prophylaxis in the management of recurrent superficial bladder carcinoma. J Urol.
737 Gateau T, Faramarzi-Roques R, Le Normand L, et al. (2003). Clinical and urodynamic repercussions after TVT procedure and how to diminish patient complaints. Eur Urol.
738 Gaudenz R, Weil A. (1980). Motor urge incontinence: diagnosis and treatment. Urol Int.
739 Gebhart JB, Dixon DA, Trabuco EC, et al. (2008). Three-year outcomes of Uretex Urethral Support System for treatment of stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
740 Gee AS, Durdey P. (1995). Urge incontinence of faeces is a marker of severe external anal sphincter dysfunction. Br J Surg.
741 Geirsson G, Fall M. (1997). Maximal functional electrical stimulation in routine practice. Neurourol Urodyn.
742 Geirsson G, Lindstrom S, Fall M. (1993). The bladder cooling reflex in man--characteristics and sensitivity to temperature. Br J Urol.
743 Geirsson G, Lindstrom S, Fall M. (1994). Pressure, volume and infusion speed criteria for the ice-water test. Br J Urol.
744 Gelenberg AJ, Kane JM, Keller MB, et al. (1989). Comparison of standard and low serum levels of lithium for maintenance treatment of bipolar disorder. N Engl J Med.
745 George J, Tharion G, Richar J, et al. (2007). The effectiveness of intravesical oxybutynin, propantheline, and capsaicin in the management of neuropathic bladder following spinal cord injury. ScientificWorldJournal.
746 George NJ, Dunn M, Dounis A, et al. (1978). The late symptomatic and functional results of enterocystoplasty. Br J Urol.
747 George VK, Russell GL, Shutt A, et al. (1991). Clam ileocystoplasty. Br J Urol.
748 Gerharz EW, Kohl UN, Weingartner K, et al. (1998). Experience with the Mainz modification of ureterosigmoidostomy. Br J Surg.
749 Gerstenberg TC, Klarskov P, Ramirez D, et al. (1986). Terodiline in the treatment of women with urgency and motor urge incontinence. A clinical and urodynamic double-blind cross-over study. Br J Urol.
750 Gerten KA, Richter HE, Burgio KL, et al. (2007). Impact of urinary incontinence in morbidly obese women versus women seeking urogynecologic care. Urology.
751 Getsios D, Caro JJ, Ishak KJ, et al. (2004). Canadian economic comparison of extended-release oxybutynin and immediate-release tolterodine in the treatment of overactive bladder. Clin Ther.
752 Getsios D, Caro JJ, Ishak KJ, et al. (2004). Oxybutynin Extended Release and Tolterodine Immediate Release: A Health Economic Comparison. Clinical Drug Investigation.
753 Ghalayini IF, Al-Ghazo MA. (2007). Intradetrusor injection of botulinum-A toxin in patients with idiopathic and neurogenic detrusor overactivity: urodynamic outcome and patient satisfaction. Neurourol Urodyn.
754 Ghei M, Malone-Lee J. (2005). Using the circumstances of symptom experience to assess the severity of urgency in the overactive bladder. J Urol.
755 Ghei M, Maraj BH, Miller R, et al. (2005). Effects of botulinum toxin B on refractory detrusor overactivity: a randomized, double-blind, placebo controlled, crossover trial. J Urol.
756 Ghezzi F, Serati M, Cromi A, et al. (2006). Tension-free vaginal tape for the treatment of urodynamic stress incontinence with intrinsic sphincteric deficiency. Int Urogynecol J Pelvic Floor Dysfunct.
757 Ghoniem GM, Lapeyrolerie J, Sood OP, et al. (1994). Tulane experience with management of urinary incontinence after placement of an artificial urinary sphincter. World J Urol.
758 Giannantoni A, Costantini E, Di Stasi SM, et al. (2006). Botulinum A toxin intravesical injections in the treatment of painful bladder syndrome: a pilot study. Eur Urol.
759 Giannantoni A, Di Stasi SM, Nardicchi V, et al. (2006). Botulinum-A toxin injections into the detrusor muscle decrease nerve growth factor bladder tissue levels in patients with neurogenic detrusor overactivity. J Urol.
760 Giannantoni A, Di Stasi SM, Stephen RL, et al. (2004). Intravesical resiniferatoxin versus botulinum-A toxin injections for neurogenic detrusor overactivity: a prospective randomized study. J Urol.
761 Giannantoni A, Mearini E, Di Stasi SM, et al. (2004). New therapeutic options for refractory neurogenic detrusor overactivity. Minerva Urol Nefrol.
762 Giannantoni A, Porena M, Costantini E, et al. (2008). Botulinum A toxin intravesical injection in patients with painful bladder syndrome: 1-year followup. J Urol.
763 Giddens JL, Radomski SB, Hirshberg ED, et al. (1999). Urodynamic findings in adults with the tethered cord syndrome. J Urol.
764 Gilja I. (2000). Tansvaginal needle suspension operation: the way we do it. Clinical and urodynamic study: long-term results. Eur Urol.
765 Gilleran JP, Lemack GE, Zimmern PE. (2006). Reduction of moderate-to-large cystocele during urodynamic evaluation using a vaginal gauze pack: 8-year experience. BJU Int.
766 Gillespie WA, Henderson EP, Linton KB, et al. (1989). Microbiology of the urethral (frequency and dysuria) syndrome. A controlled study with 5-year review. Br J Urol.
767 Gillon G, Engelstein D, Servadio C. (1992). Risk factors and their effect on the results of Burch colposuspension for urinary stress incontinence. Isr J Med Sci.
768 Gillon G, Savir A, Nissenkorn I, et al. (1989). Results and relevance of urodynamic studies in the management of urinary incontinence in women over eighty. Isr J Med Sci.
769 Giramonti KM, Kogan BA, Halpern LF. (2008). The effects of anticholinergic drugs on attention span and short-term memory skills in children. Neurourol Urodyn.
770 Girard JM, Deruelle P, Collinet P, et al. (2006). Efficacy and complications in the surgical treatment of stress urinary incontinence by insertion of a silicone-coated polyester tape (Lift). Eur J Obstet Gynecol Reprod Biol.
771 Gittes RF, Nakamura RM. (1996). Female urethral syndrome. A female prostatitis?. West J Med.
772 Giuseppe PG, Pace G, Vicentini C. (2007). Sexual function in women with urinary incontinence treated by pelvic floor transvaginal electrical stimulation. J Sex Med.
773 Gladh G, Mattsson S, Lindstrom S. (2001). Anogenital electrical stimulation as treatment of urge incontinence in children. BJU Int.
774 Gladh G, Mattsson S, Lindstrom S. (2004). Outcome of the bladder cooling test in children with nonneurogenic bladder problems. J Urol.
775 Gladman MA, Scott SM, Chan CL, et al. (2003). Rectal hyposensitivity: prevalence and clinical impact in patients with intractable constipation and fecal incontinence. Dis Colon Rectum.
776 Glavind K, Larsen EH. (2001). Results and complications of tension-free vaginal tape (TVT) for surgical treatment of female stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
777 Glazer HI, Romanzi L, Polaneczky M. (1999). Pelvic floor muscle surface electromyography. Reliability and clinical predictive validity. J Reprod Med.
778 Glazier DB, Ankem MK, Ferlise V, et al. (2001). Utility of biofeedback for the daytime syndrome of urinary frequency and urgency of childhood. Urology.
779 Glazier DB, Murphy DP, Fleisher MH, et al. (1997). Evaluation of the utility of video-urodynamics in children with urinary tract infection and voiding dysfunction. Br J Urol.
780 Glezerman M, Glasner M, Bar-David J, et al. (1986). The setting-up of an ambulatory urologic-gynecologic service. Management of patients and results. Eur J Obstet Gynecol Reprod Biol.
781 Glia A, Gylin M, Akerlund JE, et al. (1998). Biofeedback training in patients with fecal incontinence. Dis Colon Rectum.
782 Godec CJ. (1980). Detrusor hyperreflexia inhibited by anal dilatation. Urology.
783 Godec CJ, Cass AS. (1980). Cystometric variations during postural changes and functional electrical stimulation of the pelvic floor muscles. J Urol.
784 Godec CJ, Cass AS, Ruiz E. (1982). Another aspect of acute urinary retention in young patients. Ann Emerg Med.
785 Godec CJ, Esho J, Cass AS. (1980). Correlation among cystometry, urethral pressure profilometry and pelvic floor electromyography in the evaluation of female patients with voiding dysfunction symptoms. J Urol.
786 Goepel M, Hoffmann JA, Piro M, et al. (2002). Prevalence and physician awareness of symptoms of urinary bladder dysfunction. Eur Urol.
787 Goff BA, Mandel LS, Drescher CW, et al. (2007). Development of an ovarian cancer symptom index: possibilities for earlier detection. Cancer.
788 Goff BA, Mandel LS, Melancon CH, et al. (2004). Frequency of symptoms of ovarian cancer in women presenting to primary care clinics. JAMA.
789 Goffin JR, Rajan R, Souhami L. (2004). Tolerance of radiotherapy and chemotherapy in elderly patients with bladder cancer. Am J Clin Oncol.
790 Gold RS, Groutz A, Pauzner D, et al. (2007). Bladder perforation during tension-free vaginal tape surgery: does it matter?. J Reprod Med.
791 Goldberg RP, Kwon C, Gandhi S, et al. (2005). Urinary incontinence after multiple gestation and delivery: impact on quality of life. Int Urogynecol J Pelvic Floor Dysfunct.
792 Goldberg RP, Kwon C, Gandhi S, et al. (2003). Urinary incontinence among mothers of multiples: the protective effect of cesarean delivery. Am J Obstet Gynecol.
793 Goldman HB, Amundsen CL, Mangel J, et al. (2008). Dorsal genital nerve stimulation for the treatment of overactive bladder symptoms. Neurourol Urodyn.
794 Goldman HB, Dmochowski RR. (1997). Lower urinary tract dysfunction in patients with gastroparesis. J Urol.
795 Gomes CM, Hisano M, Machado LR, et al. (2005). Urological manifestations of chronic schistosomal myeloradiculopathy. BJU Int.
796 Gopal M, Haynes K, Bellamy SL, et al. (2008). Discontinuation rates of anticholinergic medications used for the treatment of lower urinary tract symptoms. Obstet Gynecol.
797 Gordon D, Gold R, Pauzner D, et al. (2005). Tension-free vaginal tape in the elderly: is it a safe procedure?. Urology.
798 Gordon D, Gold RS, Pauzner D, et al. (2001). Combined genitourinary prolapse repair and prophylactic tension-free vaginal tape in women with severe prolapse and occult stress urinary incontinence: preliminary results. Urology.
799 Gordon D, Groutz A, Ascher-Landsberg J, et al. (1998). Double-blind, placebo-controlled study of magnesium hydroxide for treatment of sensory urgency and detrusor instability: preliminary results. Br J Obstet Gynaecol.
800 Gordon D, Groutz A, Goldman G, et al. (1999). Anal incontinence: prevalence among female patients attending a urogynecologic clinic. Neurourol Urodyn.
801 Gordon D, Groutz A, Sinai T, et al. (1999). Sexual function in women attending a urogynecology clinic. Int Urogynecol J Pelvic Floor Dysfunct.
802 Gormley EA, Griffiths DJ, McCracken PN, et al. (1993). Polypharmacy and its effect on urinary incontinence in a geriatric population. Br J Urol.
803 Gorton E, Stanton S. (2000). Ambulatory urodynamics: do they help clinical management?. BJOG.
804 Graham CA, Mallett VT. (2001). Race as a predictor of urinary incontinence and pelvic organ prolapse. Am J Obstet Gynecol.
805 Graham G, Gupta S, Aarons L. (2002). Determination of an optimal dosage regimen using a Bayesian decision analysis of efficacy and adverse effect data. J Pharmacokinet Pharmacodyn.
806 Granville L. (2005). The burden of illness for overactive bladder. Manag Care Interface.
807 Graves PL, Thomas CB. (1991). Habits of nervous tension and suicide. Suicide Life Threat Behav.
808 Gravina GL, Brandetti F, Martini P, et al. (2008). Measurement of the thickness of the urethrovaginal space in women with or without vaginal orgasm. J Sex Med.
809 Gray M, Albo M, Huffstutler S. (2002). Interstitial cystitis: a guide to recognition, evaluation, and management for nurse practitioners. J Wound Ostomy Continence Nurs.
810 Gray M, McClain R, Peruggia M, et al. (2001). A model for predicting motor urge urinary incontinence. Nurs Res.
811 Gray R, Wagg A, Malone-Lee JG. (1997). Differences in detrusor contractile function in women with neuropathic and idiopathic detrusor instability. Br J Urol.
812 Green M, Filippou A, Sant G, et al. (2004). Expression of intercellular adhesion molecules in the bladder of patients with interstitial cystitis. Urology.
813 Green SA, Alon A, Ianus J, et al. (2006). Efficacy and safety of a neurokinin-1 receptor antagonist in postmenopausal women with overactive bladder with urge urinary incontinence. J Urol.
814 Greenberg P, Brown J, Yates T, et al. (2008). Voiding urges perceived by patients with interstitial cystitis/painful bladder syndrome. Neurourol Urodyn.
815 Greenfield S, Friedland G, Scifers S, et al. (1974). Protocol management of dysuria, urinary frequency, and vaginal discharge. Ann Intern Med.
816 Greenfield S, Friedland G, Scifers S, et al. (1975). Protocol management of dysuria, urinary frequency, and vaginal discharge. J Fam Pract.
817 Griffiths D. (1998). Clinical studies of cerebral and urinary tract function in elderly people with urinary incontinence. Behav Brain Res.
818 Griffiths D, Derbyshire S, Stenger A, et al. (2005). Brain control of normal and overactive bladder. J Urol.
819 Griffiths D, Tadic SD, Schaefer W, et al. (2007). Cerebral control of the bladder in normal and urge-incontinent women. Neuroimage.
820 Griffiths DJ. (1977). Urodynamic assessment of bladder function. Br J Urol.
821 Griffiths DJ, McCracken PN, Harrison GM. (1991). Incontinence in the elderly: objective demonstration and quantitative assessment. Br J Urol.
822 Griffiths DJ, McCracken PN, Harrison GM, et al. (1992). Characteristics of urinary incontinence in elderly patients studied by 24-hour monitoring and urodynamic testing. Age Ageing.
823 Griffiths DJ, McCracken PN, Harrison GM, et al. (1993). Relationship of fluid intake to voluntary micturition and urinary incontinence in geriatric patients. Neurourol Urodyn.
824 Griffiths DJ, McCracken PN, Harrison GM, et al. (1994). Cerebral aetiology of urinary urge incontinence in elderly people. Age Ageing.
825 Griffiths DJ, McCracken PN, Harrison GM, et al. (2002). Urge incontinence and impaired detrusor contractility in the elderly. Neurourol Urodyn.
826 Griffiths DJ, McCracken PN, Harrison GM, et al. (1994). Urinary incontinence in the elderly: the brain factor. Scand J Urol Nephrol Suppl.
827 Griffiths DJ, McCracken PN, Harrison GM, et al. (1996). Urge incontinence in elderly people: factors predicting the severity of urine loss before and after pharmacological treatment. Neurourol Urodyn.
828 Griffiths DJ, Scholtmeijer RJ. (1984). Place of the free flow curve in the urodynamic investigation of children. Br J Urol.
829 Grigoleit U, Murtz G, Laschke S, et al. (2006). Efficacy, tolerability and safety of propiverine hydrochloride in children and adolescents with congenital or traumatic neurogenic detrusor overactivity--a retrospective study. Eur Urol.
830 Grimby A, Milsom I, Molander U, et al. (1993). The influence of urinary incontinence on the quality of life of elderly women. Age Ageing.
831 Grischke EM, Anton H, Stolz W, et al. (1991). Urodynamic assessment and lateral urethrocystography. A comparison of two diagnostic procedures for female urinary incontinence. Acta Obstet Gynecol Scand.
832 Groen J, Amiel C, Bosch JL. (2005). Chronic pudendal nerve neuromodulation in women with idiopathic refractory detrusor overactivity incontinence: results of a pilot study with a novel minimally invasive implantable mini-stimulator. Neurourol Urodyn.
833 Groen J, Klijn AJ, Bosch JL, et al. (1998). Diagnosis and grading of detrusor instability using a computerized algorithm. J Urol.
834 Groen J, Ruud Bosch JL, van Mastrigt R. (2006). Sacral neuromodulation in women with idiopathic detrusor overactivity incontinence: decreased overactivity but unchanged bladder contraction strength and urethral resistance during voiding. J Urol.
835 Groen J, van Mastrigt R, Bosch JL. (2001). Computerized assessment of detrusor instability in patients treated with sacral neuromodulation. J Urol.
836 Groenendijk PM, Halilovic M, Chandi DD, et al. (2008). Extracorporeal magnetic innervation therapy: assessment of clinical efficacy in relation to urodynamic parameters. Scand J Urol Nephrol.
837 Groenendijk PM, Heesakkers JP, Lycklama ANAA. (2007). Urethral instability and sacral nerve stimulation-a better parameter to predict efficacy?. J Urol.
838 Grosse J, Kramer G, Stohrer M. (2005). Success of repeat detrusor injections of botulinum a toxin in patients with severe neurogenic detrusor overactivity and incontinence. Eur Urol.
839 Grossklaus DJ, Franke JJ. (2000). Treatment of elderly women with urge incontinence in middle tennessee: a single institution practice-based study. Tenn Med.
840 Groutz A, Blaivas JG, Hyman MJ, et al. (2001). Pubovaginal sling surgery for simple stress urinary incontinence: analysis by an outcome score. J Urol.
841 Groutz A, Blaivas JG, Kesler SS, et al. (2000). Outcome results of transurethral collagen injection for female stress incontinence: assessment by urinary incontinence score. J Urol.
842 Groutz A, Chaikin DC, Theusen E, et al. (2001). Use of cadaveric solvent-dehydrated fascia lata for cystocele repair--preliminary results. Urology.
843 Groutz A, Gold R, Pauzner D, et al. (2004). Tension-free vaginal tape (TVT) for the treatment of occult stress urinary incontinence in women undergoing prolapse repair: a prospective study of 100 consecutive cases. Neurourol Urodyn.
844 Groutz A, Gordon D, Wolman I, et al. (2001). Persistent postpartum urinary retention in contemporary obstetric practice. Definition, prevalence and clinical implications. J Reprod Med.
845 Groutz A, Gordon D, Wolman I, et al. (2002). Tension-free vaginal tape for stress urinary incontinence: Is there a learning curve?. Neurourol Urodyn.
846 Groutz A, Samandarov A, Gold R, et al. (2001). Role of urethrocystoscopy in the evaluation of refractory idiopathic detrusor instability. Urology.
847 Gruneberger A. (1984). Treatment of motor urge incontinence with clenbuterol and flavoxate hydrochloride. Br J Obstet Gynaecol.
848 Gu FL, Reng ZY, Shang GZ, et al. (1987). Treatment of urgency and urge incontinence with flavoxate in the People’s Republic of China. J Int Med Res.
849 Gu J, Restorick JM, Blank MA, et al. (1983). Vasoactive intestinal polypeptide in the normal and unstable bladder. Br J Urol.
850 Guarisi T, Pinto-Neto AM, Herrmann V, et al. (2002). Urodynamics in climacteric women with urinary incontinence: correlation with route of delivery. Int Urogynecol J Pelvic Floor Dysfunct.
851 Guerette NL, Bena JF, Davila GW. (2008). Transobturator slings for stress incontinence: using urodynamic parameters to predict outcomes. Int Urogynecol J Pelvic Floor Dysfunct.
852 Guerra LA, Pike J, Milks J, et al. (2006). Outcome in patients who underwent tethered cord release for occult spinal dysraphism. J Urol.
853 Guerrero K, Emery S, Owen L, et al. (2006). Intravesical oxybutynin: practicalities of clinical use. J Obstet Gynaecol.
854 Gunnarsson M, Mattiasson A. (1994). Circumvaginal surface electromyography in women with urinary incontinence and in healthy volunteers. Scand J Urol Nephrol Suppl.
855 Haab F, Richard F, Amarenco G, et al. (2008). Comprehensive evaluation of bladder and urethral dysfunction symptoms: development and psychometric validation of the Urinary Symptom Profile (USP) questionnaire. Urology.
856 Haab F, Sananes S, Amarenco G, et al. (2001). Results of the tension-free vaginal tape procedure for the treatment of type II stress urinary incontinence at a minimum followup of 1 year. J Urol.
857 Haarala M, Alanen A, Hietarinta M, et al. (2000). Lower urinary tract symptoms in patients with Sjogren’s syndrome and systemic lupus erythematosus. Int Urogynecol J Pelvic Floor Dysfunct.
858 Haeusler G, Hanzal E, Joura E, et al. (1995). Differential diagnosis of detrusor instability and stress-incontinence by patient history: the Gaudenz-Incontinence-Questionnaire revisited. Acta Obstet Gynecol Scand.
859 Haferkamp A, Dorsam J, Elbadawi A. (2003). Ultrastructural diagnosis of neuropathic detrusor overactivity: validation of a common myogenic mechanism. Adv Exp Med Biol.
860 Haferkamp A, Dorsam J, Resnick NM, et al. (2003). Structural basis of neurogenic bladder dysfunction. II. Myogenic basis of detrusor hyperreflexia. J Urol.
861 Haferkamp A, Freund T, Wagener N, et al. (2006). Distribution of neuropeptide Y-containing nerves in the neurogenic and non-neurogenic detrusor. BJU Int.
862 Haferkamp A, Mundhenk J, Bastian PJ, et al. (2004). Increased expression of connexin 43 in the overactive neurogenic detrusor. Eur Urol.
863 Haferkamp A, Schurch B, Reitz A, et al. (2004). Lack of ultrastructural detrusor changes following endoscopic injection of botulinum toxin type a in overactive neurogenic bladder. Eur Urol.
864 Hagglund D, Walker-Engstrom ML, Larsson G, et al. (2001). Quality of life and seeking help in women with urinary incontinence. Acta Obstet Gynecol Scand.
865 Hains G, Hains F, Descarreaux M, et al. (2007). Urinary incontinence in women treated by ischemic compression over the bladder area: a pilot study. Journal of Chiropractic Medicine.
866 Hajebrahimi S, Altaweel W, Cadoret J, et al. (2005). Efficacy of botulinum-A toxin in adults with neurogenic overactive bladder: initial results. Can J Urol.
867 Hallen B, Bogentoft S, Sandquist S, et al. (1989). Tolerability and steady-state pharmacokinetics of terodiline and its main metabolites in elderly patients with urinary incontinence. Eur J Clin Pharmacol.
868 Hampel C, Wienhold D, Benken N, et al. (1997). Definition of overactive bladder and epidemiology of urinary incontinence. Urology.
869 Hancock R, Bender P, Dayhoff N, et al. (1996). Factors associated with nursing interventions to reduce incontinence in hospitalized older adults. Urol Nurs.
870 Handa VL, Harvey L, Fox HE, et al. (2004). Parity and route of delivery: does cesarean delivery reduce bladder symptoms later in life?. Am J Obstet Gynecol.
871 Hanley HG. (1965). Urge incontinence. Br J Urol.
872 Hannestad YS, Lie RT, Rortveit G, et al. (2004). Familial risk of urinary incontinence in women: population based cross sectional study. BMJ.
873 Hanno PM. (1997). Analysis of long-term Elmiron therapy for interstitial cystitis. Urology.
874 Hanno PM, Buehler J, Wein AJ. (1989). Use of amitriptyline in the treatment of interstitial cystitis. J Urol.
875 Hanno PM, Landis JR, Matthews-Cook Y, et al. (1999). The diagnosis of interstitial cystitis revisited: lessons learned from the National Institutes of Health Interstitial Cystitis Database study. J Urol.
876 Hansen BM, Bonnesen T, Hvidberg JE, et al. (1985). Changes in symptoms and colpo-cystourethrography in 35 patients before and after total abdominal hysterectomy: a prospective study. Urol Int.
877 Hansen J, Borau A, Rodriguez A, et al. (2007). Urethral sphincter EMG as event detector for Neurogenic detrusor overactivity. IEEE Trans Biomed Eng.
878 Hansen J, Media S, Nohr M, et al. (2005). Treatment of neurogenic detrusor overactivity in spinal cord injured patients by conditional electrical stimulation. J Urol.
879 Hanson LA, Schulz JA, Flood CG, et al. (2006). Vaginal pessaries in managing women with pelvic organ prolapse and urinary incontinence: patient characteristics and factors contributing to success. Int Urogynecol J Pelvic Floor Dysfunct.
880 Hansson S, Hjalmas K, Jodal U, et al. (1990). Lower urinary tract dysfunction in girls with untreated asymptomatic or covert bacteriuria. J Urol.
881 Harding C, Dorkin TJ, Thorpe AC. (2009). Is low bladder compliance predictive of detrusor overactivity?. Neurourol Urodyn.
882 Harding G, Cella D, Robinson D, et al. (2007). Symptom burden among patients with renal cell carcinoma (RCC): content for a symptom index. Health Qual Life Outcomes.
883 Hardy BG, Shulman KI, Zucchero C. (1997). Gradual discontinuation of lithium augmentation in elderly patients with unipolar depression. J Clin Psychopharmacol.
884 Harms L, Emons G, Bader W, et al. (2007). Funneling before and after anti-incontinence surgery--a prognostic indicator? Part 2: tension-free vaginal tape. Int Urogynecol J Pelvic Floor Dysfunct.
885 Harpe SE, Szeinbach SL, Caswell RJ, et al. (2007). The relative importance of health related quality of life and prescription insurance coverage in the decision to pharmacologically manage symptoms of overactive bladder. J Urol.
886 Harper M, Popat RB, Dasgupta R, et al. (2003). A minimally invasive technique for outpatient local anaesthetic administration of intradetrusor botulinum toxin in intractable detrusor overactivity. BJU Int.
887 Harris RL, Cundiff GW, Coates KW, et al. (1998). Urinary incontinence and pelvic organ prolapse in nulliparous women. Obstet Gynecol.
888 Harris RL, Cundiff GW, Theofrastous JP, et al. (1996). Bladder compliance in neurologically intact women. Neurourol Urodyn.
889 Harrison GL, Memel DS. (1994). Urinary incontinence in women: its prevalence and its management in a health promotion clinic. Br J Gen Pract.
890 Hartigan-Go K, Bateman DN, Daly AK, et al. (1996). Stereoselective cardiotoxic effects of terodiline. Clin Pharmacol Ther.
891 Hartnett NM, Saver BG. (2001). Is extended-release oxybutynin (Ditropan XL) or tolterodine (Detrol) more effective in the treatment of an overactive bladder?. J Fam Pract.
892 Harvey MA, Baker K, Wells GA. (2001). Tolterodine versus oxybutynin in the treatment of urge urinary incontinence: a meta-analysis. Am J Obstet Gynecol.
893 Hasan ST, Marshall C, Robson WA, et al. (1995). Clinical outcome and quality of life following enterocystoplasty for idiopathic detrusor instability and neurogenic bladder dysfunction. Br J Urol.
894 Hasan ST, Robson WA, Pridie AK, et al. (1996). Transcutaneous electrical nerve stimulation and temporary S3 neuromodulation in idiopathic detrusor instability. J Urol.
895 Hasan ST, Robson WA, Ramsden PD, et al. (1995). Outcome of endoscopic bladder transection. Br J Urol.
896 Hashim H, Abrams P. (2006). Is the bladder a reliable witness for predicting detrusor overactivity?. J Urol.
897 Hashim H, Abrams P. (2008). How should patients with an overactive bladder manipulate their fluid intake?. BJU Int.
898 Hashim H, Malmberg L, Graugaard-Jensen C, et al. (2009). Desmopressin, as a “designer-drug,” in the treatment of overactive bladder syndrome. Neurourol Urodyn.
899 Hassouna ME, Ghoniem GM. (1999). Long-term outcome and quality of life after modified pubovaginal sling for intrinsic sphincteric deficiency. Urology.
900 Hastie KJ, Moisey CU. (1989). Are urodynamics necessary in female patients presenting with stress incontinence?. Br J Urol.
901 Hastwell GB. (1986). Psychogenic pelvic pain or occult prolapse syndrome?. Med J Aust.
902 Hattori T, Yasuda K, Sakakibara R, et al. (1990). Micturitional disturbance in ossification of the posterior longitudinal ligament in the cervical spine. J Spinal Disord.
903 Haylen BT, Chetty N, Logan V, et al. (2007). Is sensory urgency part of the same spectrum of bladder dysfunction as detrusor overactivity?. Int Urogynecol J Pelvic Floor Dysfunct.
904 Haylen BT, Krishnan S, Schulz S, et al. (2007). Has the true prevalence of voiding difficulty in urogynecology patients been underestimated?. Int Urogynecol J Pelvic Floor Dysfunct.
905 Haylen BT, Parys BT, Anyaegbunam WI, et al. (1990). Urine flow rates in male and female urodynamic patients compared with the Liverpool nomograms. Br J Urol.
906 Haylen BT, Sutherst JR, Frazer MI. (1989). Is the investigation of most stress incontinence really necessary?. Br J Urol.
907 Hebjorn S. (1977). Treatment of detrusor hyperreflexia in multiple sclerosis: a double-blind, crossover clinical trial comparing methantheline bromide (Banthine), flavoxate chloride (Urispas) and meladrazine tartrate (Lisidonil). Urol Int.
908 Hebjorn S, Andersen JT, Walter S, et al. (1976). Detrusor hyperreflexia. A survey on its etiology and treatment. Scand J Urol Nephrol.
909 Heckerling PS, Canaris GJ, Flach SD, et al. (2007). Predictors of urinary tract infection based on artificial neural networks and genetic algorithms. Int J Med Inform.
910 Hedlund H, Schultz A, Talseth T, et al. (2002). Sacral neuromodulation in Norway: clinical experience of the first three years. Scand J Urol Nephrol Suppl.
911 Heilenkotter K, Bachmann C, Janhsen E, et al. (2006). Prospective evaluation of inpatient and outpatient bladder training in children with functional urinary incontinence. Urology.
912 Hellerstein S, Linebarger JS. (2003). Voiding dysfunction in pediatric patients. Clin Pediatr (Phila).
913 Hellerstein S, Zguta AA. (2003). Outcome of overactive bladder in children. Clin Pediatr (Phila).
914 Hellstrom AL, Hjalmas K, Jodal U. (1989). Terodiline in the treatment of children with unstable bladders. Br J Urol.
915 Hellstrom PA, Tammela TL, Kontturi MJ, et al. (1991). The bladder cooling test for urodynamic assessment: analysis of 400 examinations. Br J Urol.
916 Henningsohn L, Steven K, Kallestrup EB, et al. (2002). Distressful symptoms and well-being after radical cystectomy and orthotopic bladder substitution compared with a matched control population. J Urol.
917 Herbst F, Kamm MA, Morris GP, et al. (1997). Gastrointestinal transit and prolonged ambulatory colonic motility in health and faecal incontinence. Gut.
918 Herwig R, Bruns F, Strasser H, et al. (2004). Late urologic effects after adjuvant irradiation in stage I endometrial carcinoma. Urology.
919 Heslington K, Hilton P. (1996). Ambulatory monitoring and conventional cystometry in asymptomatic female volunteers. Br J Obstet Gynaecol.
920 Hicks A, McCafferty GP, Riedel E, et al. (2007). GW427353 (solabegron), a novel, selective beta3-adrenergic receptor agonist, evokes bladder relaxation and increases micturition reflex threshold in the dog. J Pharmacol Exp Ther.
921 Higson RH, Smith JC, Hills W. (1979). Intravesical lignocaine and detrusor instability. Br J Urol.
922 Higson RH, Smith JC, Whelan P. (1978). Bladder rupture: an acceptable complication of distension therapy?. Br J Urol.
923 Hill J, Corson RJ, Brandon H, et al. (1994). History and examination in the assessment of patients with idiopathic fecal incontinence. Dis Colon Rectum.
924 Hilton P. (1988). Urinary incontinence during sexual intercourse: a common, but rarely volunteered, symptom. Br J Obstet Gynaecol.
925 Hilton P. (1989). A clinical and urodynamic study comparing the Stamey bladder neck suspension and suburethral sling procedures in the treatment of genuine stress incontinence. Br J Obstet Gynaecol.
926 Hilton P. (1998). Urodynamic findings in patients with urogenital fistulae. Br J Urol.
927 Hilton P, Mayne CJ. (1991). The Stamey endoscopic bladder neck suspension: a clinical and urodynamic investigation, including actuarial follow-up over four years. Br J Obstet Gynaecol.
928 Hilton P, Stanton SL. (1982). The use of desmopressin (DDAVP) in nocturnal urinary frequency in the female. Br J Urol.
929 Hinata N, Shirakawa T, Okada H, et al. (2004). Quantitative analysis of the levels of expression of muscarinic receptor subtype RNA in the detrusor muscle of patients with overactive bladder. Mol Diagn.
930 Hindmarsh JR, Essenhigh DM, Yeates WK. (1978). Indications for bladder transection. Urol Int.
931 Hindmarsh JR, Gosling PT, Deane AM. (1983). Bladder instability. Is the primary defect in the urethra?. Br J Urol.
932 Hirao Y, Okajima E, Ozono S, et al. (1992). A prospective randomized study of prophylaxis of tumor recurrence following transurethral resection of superficial bladder cancer--intravesical thio-TEPA versus oral UFT. Cancer Chemother Pharmacol.
933 Hirst GR, Watkins AJ, Guerrero K, et al. (2007). Botulinum toxin B is not an effective treatment of refractory overactive bladder. Urology.
934 Hitchcock RJ, Duffy PG, Malone PS. (1994). Ureterocystoplasty: the ‘bladder’ augmentation of choice. Br J Urol.
935 Hjalmas K, Hellstrom AL, Mogren K, et al. (2001). The overactive bladder in children: a potential future indication for tolterodine. BJU Int.
936 Ho CH, Chen SC, Chung SD, et al. (2008). Determining the appropriate length of a double-pigtail ureteral stent by both stent configurations and related symptoms. J Endourol.
937 Hodgkinson CP, Drukker BH. (1977). Infravesical nerve resection for detrusor dyssynergia. The Ingelman-Sundberg operation. Acta Obstet Gynecol Scand.
938 Hoebeke P, De Caestecker K, Vande Walle J, et al. (2006). The effect of botulinum-A toxin in incontinent children with therapy resistant overactive detrusor. J Urol.
939 Hoebeke P, Van Laecke E, Everaert K, et al. (2001). Transcutaneous neuromodulation for the urge syndrome in children: a pilot study. J Urol.
940 Hoebeke P, Van Laecke E, Renson C, et al. (2004). Pelvic floor spasms in children: an unknown condition responding well to pelvic floor therapy. Eur Urol.
941 Hoebeke P, Van Laecke E, Van Camp C, et al. (2001). One thousand video-urodynamic studies in children with non-neurogenic bladder sphincter dysfunction. BJU Int.
942 Hoebeke PB, Van Gool JD, Van Laecke E, et al. (1996). The after-contraction in paediatric urodynamics. Br J Urol.
943 Hoekx L, Vermandel A, Wyndaele JJ. (2003). Functional bladder capacity after bladder biofeedback predicts long-term outcome in children with nocturnal enuresis. Scand J Urol Nephrol.
944 Hoekx L, Wyndaele JJ, Vermandel A. (1998). The role of bladder biofeedback in the treatment of children with refractory nocturnal enuresis associated with idiopathic detrusor instability and small bladder capacity. J Urol.
945 Holmes DM, Montz FJ, Stanton SL. (1989). Oxybutinin versus propantheline in the management of detrusor instability. A patient-regulated variable dose trial. Br J Obstet Gynaecol.
946 Holmes DM, Plevnik S, Stanton SL. (1989). Bladder neck electrical conductivity in female urinary urgency and urge incontinence. Br J Obstet Gynaecol.
947 Holmes DM, Plevnik S, Stanton SL. (1989). Bladder neck electrical conductivity in the treatment of detrusor instability with biofeedback. Br J Obstet Gynaecol.
948 Holmes NM, Coplen DE, Strand W, et al. (2002). Is bladder dysfunction and incontinence associated with ureteroceles congenital or acquired?. J Urol.
949 Holmgren C, Nilsson S, Lanner L, et al. (2007). Frequency of de novo urgency in 463 women who had undergone the tension-free vaginal tape (TVT) procedure for genuine stress urinary incontinence--a long-term follow-up. Eur J Obstet Gynecol Reprod Biol.
950 Holschneider CH, Solh S, Lebherz TB, et al. (1994). The modified Pereyra procedure in recurrent stress urinary incontinence: a 15-year review. Obstet Gynecol.
951 Homayoon K, Chen JJ, Cummings JM, et al. (2005). Voiding dysfunction: outcome in infants with congenital vesicoureteral reflux. Urology.
952 Homma Y, Kawabe K. (2004). Health-related quality of life of Japanese patients with overactive bladder treated with extended-release tolterodine or immediate-release oxybutynin: a randomized, placebo-controlled trial. World J Urol.
953 Homma Y, Kondo Y, Takahashi S, et al. (2000). Reproducibility of cystometry in overactive detrusor. Eur Urol.
954 Homma Y, Paick JS, Lee JG, et al. (2003). Clinical efficacy and tolerability of extended-release tolterodine and immediate-release oxybutynin in Japanese and Korean patients with an overactive bladder: a randomized, placebo-controlled trial. BJU Int.
955 Homma Y, Uemura S. (2004). Use of the short form of King’s Health Questionnaire to measure quality of life in patients with an overactive bladder. BJU Int.
956 Homma Y, Yamaguchi T, Yamaguchi O. (2008). A randomized, double-blind, placebo-controlled phase II dose-finding study of the novel anti-muscarinic agent imidafenacin in Japanese patients with overactive bladder. Int J Urol.
957 Homma Y, Yoshida M, Seki N, et al. (2006). Symptom assessment tool for overactive bladder syndrome--overactive bladder symptom score. Urology.
958 Hooper P, Tincello DG, Richmond DH. (1997). The use of salivary stimulant pastilles to improve compliance in women taking oxybutynin hydrochloride for detrusor instability: a pilot study. Br J Urol.
959 Horstmann M, Schaefer T, Aguilar Y, et al. (2006). Neurogenic bladder treatment by doubling the recommended antimuscarinic dosage. Neurourol Urodyn.
960 Hougaard C, Fraser MO, Chien C, et al. (2009). A positive modulator of K Ca 2 and K Ca 3 channels, 4,5-dichloro-1,3-diethyl-1,3-dihydro-benzoimidazol-2-one (NS4591), inhibits bladder afferent firing in vitro and bladder overactivity in vivo. J Pharmacol Exp Ther.
961 Hoverd PA, Fowler CJ. (1998). Desmopressin in the treatment of daytime urinary frequency in patients with multiple sclerosis. J Neurol Neurosurg Psychiatry.
962 Ho-Yin PL, Man-Wah P, Shing-Kai Y. (2003). Effects of aging on generic SF-36 quality of life measurements in Hong Kong Chinese women with urinary incontinence. Acta Obstet Gynecol Scand.
963 Hsieh CH, Chen HY, Hsu CS, et al. (2006). Risk factors for urinary frequency in Taiwanese women aged 20–59 years. Taiwan J Obstet Gynecol.
964 Hsieh TF, Yu KJ, Lin SY. (2007). Possible application of Raman microspectroscopy to verify the interstitial cystitis diagnosis after potassium sensitivity test: phenylalanine or tryptophan as a biomarker. Dis Markers.
965 Hu TW, Wagner TH. (2005). Health-related consequences of overactive bladder: an economic perspective. BJU Int.
966 Hu TW, Wagner TH, Bentkover JD, et al. (2004). Costs of urinary incontinence and overactive bladder in the United States: a comparative study. Urology.
967 Huang KH, Kung FT, Liang HM, et al. (2005). Management of polypropylene mesh erosion after intravaginal midurethral sling operation for female stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
968 Huang KH, Kung FT, Liang HM, et al. (2006). Concomitant pelvic organ prolapse surgery with TVT procedure. Int Urogynecol J Pelvic Floor Dysfunct.
969 Huang KH, Kung FT, Liang HM, et al. (2003). Concomitant surgery with tension-free vaginal tape. Acta Obstet Gynecol Scand.
970 Hubeaux K, Deffieux X, Ismael SS, et al. (2007). Autonomic nervous system activity during bladder filling assessed by heart rate variability analysis in women with idiopathic overactive bladder syndrome or stress urinary incontinence. J Urol.
971 Hughes DA, Dubois D. (2004). Cost-effectiveness analysis of extended-release formulations of oxybutynin and tolterodine for the management of urge incontinence. Pharmacoeconomics.
972 Hui-Chi H. (2004). A checklist for assessing the risk of falls among the elderly. J Nurs Res.
973 Hullfish KL, Bovbjerg VE, Steers WD. (2007). Colpocleisis for pelvic organ prolapse: patient goals, quality of life, and satisfaction. Obstet Gynecol.
974 Hullfish KL, Fenner DE, Sorser SA, et al. (2007). Postpartum depression, urge urinary incontinence, and overactive bladder syndrome: is there an association?. Int Urogynecol J Pelvic Floor Dysfunct.
975 Hung MJ, Ho ES, Shen PS, et al. (2006). Urgency is the core symptom of female overactive bladder syndrome, as demonstrated by a statistical analysis. J Urol.
976 Hutchings A, Griffiths J, Black NA. (1998). Surgery for stress incontinence: factors associated with a successful outcome. Br J Urol.
977 Huwyler M, Schurch B, Knapp PA, et al. (2007). Can the ice-water test predict the outcome of intradetrusor injections of botulinum toxin in patients with neurogenic bladder dysfunction?. World J Urol.
978 Huwyler M, Springer J, Kessler TM, et al. (2008). A safe and simple solution for intravesical tension-free vaginal tape erosion: removal by standard transurethral resection. BJU Int.
979 Iglesias X, Espuna M. (2003). Surgical treatment of urinary stress incontinence using a method for postoperative adjustment of sling tension (Remeex System). Int Urogynecol J Pelvic Floor Dysfunct.
980 Ijland MM, Fischer DC, Kieback DG, et al. (2005). Midline intravaginal slingplasty for treatment of urinary stress incontinence: results of an independent audit up to 2 years after surgery. Int Urogynecol J Pelvic Floor Dysfunct.
981 Ikeda K, Kobayashi S, Suzuki M, et al. (2002). M(3) receptor antagonism by the novel antimuscarinic agent solifenacin in the urinary bladder and salivary gland. Naunyn Schmiedebergs Arch Pharmacol.
982 Ilker Y, Tarcan T, Ozveren B, et al. (2003). Anterior urethropexy according to lapides: how effective is it in the treatment of genuine female stress incontinence?. Arch Esp Urol.
983 Imanishi M, Tomishima Y, Itou S, et al. (2008). Discovery of a novel series of biphenyl benzoic acid derivatives as potent and selective human beta3-adrenergic receptor agonists with good oral bioavailability. Part I. J Med Chem.
984 Ingelman-Sundberg A. (1975). Urge incontinence in women. Acta Obstet Gynecol Scand.
985 Iosif S, Henriksson L, Ulmsten U. (1980). Urethrocystometry as a routine method for the objective evaluation of women with urinary incontinence. Arch Gynecol.
986 Iosif S, Henriksson L, Ulmsten U. (1981). The frequency of disorders of the lower urinary tract, urinary incontinence in particular, as evaluated by a questionnaire survey in a gynecological health control population. Acta Obstet Gynecol Scand.
987 Irwin DE, Abrams P, Milsom I, et al. (2008). Understanding the elements of overactive bladder: questions raised by the EPIC study. BJU Int.
988 Irwin DE, Milsom I, Kopp Z, et al. (2008). Symptom bother and health care-seeking behavior among individuals with overactive bladder. Eur Urol.
989 Irwin DE, Milsom I, Kopp Z, et al. (2006). Impact of overactive bladder symptoms on employment, social interactions and emotional well-being in six European countries. BJU Int.
990 Irwin P, Samsudin A. (2005). Reinvestigation of patients with a diagnosis of interstitial cystitis: common things are sometimes common. J Urol.
991 Irwin PP, Hammonds WD, Galloway NT. (1993). Lumbar epidural blockade for management of pain in interstitial cystitis. Br J Urol.
992 Ishigooka M, Hashimoto T, Hayami S, et al. (1997). Ice water test in patients with overactive bladder due to cerebrovascular accidents and bladder outlet obstruction. Urol Int.
993 Ishigooka M, Hashimoto T, Izumiya K, et al. (1993). Electrical pelvic floor stimulation in the management of urinary incontinence due to neuropathic overactive bladder. Front Med Biol Eng.
994 Ishigooka M, Hashimoto T, Sasagawa I, et al. (1992). Terodiline in the treatment of nocturnal enuresis in children. Int Urol Nephrol.
995 Ishigooka M, Hashimoto T, Sasagawa I, et al. (1994). Electrical pelvic floor stimulation by percutaneous implantable electrode. Br J Urol.
996 Ishigooka M, Zermann DH, Doggweiler R, et al. (1999). Sacral nerve stimulation and diurnal urine volume. Eur Urol.
997 Ishikawa N, Suda S, Sasaki T, et al. (1998). Development of a non-invasive treatment system for urinary incontinence using a functional continuous magnetic stimulator (FCMS). Med Biol Eng Comput.
998 Ishiko O, Hirai K, Sumi T, et al. (2000). The urinary incontinence score in the diagnosis of female urinary incontinence. Int J Gynaecol Obstet.
999 Ishiko O, Sumi T, Hirai K, et al. (2000). Classification of female urinary incontinence by the scored incontinence questionnaire. Int J Gynaecol Obstet.
1000 Ismael SS, Epstein T, Bayle B, et al. (2000). Bladder cooling reflex in patients with multiple sclerosis. J Urol.
1001 Ismail SI. (2007). Recurrent prolapse after sacrocolpopexy for post-hysterectomy vaginal vault prolapse. J Obstet Gynaecol.
1002 Ito T, Sakakibara R, Yamamoto T, et al. (2006). Urinary dysfunction and autonomic control in amyloid neuropathy. Clin Auton Res.
1003 Ito T, Sakakibara R, Yasuda K, et al. (2006). Incomplete emptying and urinary retention in multiple-system atrophy: when does it occur and how do we manage it?. Mov Disord.
1004 Ito T, Ueda T, Honma Y, et al. (2007). Recent trends in patient characteristics and therapeutic choices for interstitial cystitis: analysis of 282 Japanese patients. Int J Urol.
1005 Ivil KD, Suresh G. (2002). Review of augmentation ‘clam’ cystoplasy in a district general hospital setting. Int Urol Nephrol.
1006 Jackson RA, Vittinghoff E, Kanaya AM, et al. (2004). Urinary incontinence in elderly women: findings from the Health, Aging, and Body Composition Study. Obstet Gynecol.
1007 Jackson SL, Scholes D, Boyko EJ, et al. (2005). Urinary incontinence and diabetes in postmenopausal women. Diabetes Care.
1008 Jacobs CD, van der Pas M. (1996). A multicenter maintenance study of oral pilocarpine tablets for radiation-induced xerostomia. Oncology (Williston Park).
1009 Jacoby K, Rowbotham RK. (1999). Double balloon positive pressure urethrography is a more sensitive test than voiding cystourethrography for diagnosing urethral diverticulum in women. J Urol.
1010 Jacome EG, Tutera G, Mattox FT. (1999). Laparoscopic Burch urethropexy in a private clinical practice. J Am Assoc Gynecol Laparosc.
1011 James ED, Niblett PG. (1988). Provisional study to quantify and compare parameters of urine leakage in stress and instability incontinence. Br J Urol.
1012 James M, Jackson S, Shepherd A, et al. (1999). Pure stress leakage symptomatology: is it safe to discount detrusor instability?. Br J Obstet Gynaecol.
1013 Janknegt RA, Weil EH, Eerdmans PH. (1997). Improving neuromodulation technique for refractory voiding dysfunctions: two-stage implant. Urology.
1014 Jankovic J, Gilden JL, Hiner BC, et al. (1993). Neurogenic orthostatic hypotension: a double-blind, placebo-controlled study with midodrine. Am J Med.
1015 Jansen L, Forbes D. (2006). The psychometric testing of a urinary incontinence nursing assessment instrument. J Wound Ostomy Continence Nurs.
1016 Jarvis GJ. (1982). The management of urinary incontinence due to primary vesical sensory urgency by bladder drill. Br J Urol.
1017 Jarvis GJ, Millar DR. (1981). The treatment of incontinence due to detrusor instability by bladder drill. Prog Clin Biol Res.
1018 Jeffery S, Fynes M, Lee F, et al. (2007). Efficacy and complications of intradetrusor injection with botulinum toxin A in patients with refractory idiopathic detrusor overactivity. BJU Int.
1019 Jensen LN, Gerstenberg T, Kallestrup EB, et al. (1998). Urodynamic evaluation of patients with autosomal dominant pure spastic paraplegia linked to chromosome 2p21-p24. J Neurol Neurosurg Psychiatry.
1020 Jeon MJ, Chung da J, Park JH, et al. (2008). Surgical therapeutic index of tension-free vaginal tape and transobturator tape for stress urinary incontinence. Gynecol Obstet Invest.
1021 Jha S, Moran P, Greenham H, et al. (2007). Sexual function following surgery for urodynamic stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
1022 Jha S, Toozs-Hobson P, Parsons M, et al. (2008). Does preoperative urodynamics change the management of prolapse?. J Obstet Gynaecol.
1023 Jitapunkul S, Khovidhunkit W. (1998). Urinary incontinence in Thai elderly living in Klong Toey slum. J Med Assoc Thai.
1024 Johannesson M, O’Conor RM, Kobelt-Nguyen G, et al. (1997). Willingness to pay for reduced incontinence symptoms. Br J Urol.
1025 Johansen J, Claudi T, Holtedahl K. (1999). Insulin treatment for poorly regulated diabetic patients in general practice. Better regulation and symptom relief?. Scand J Prim Health Care.
1026 Johnson DN, Vaglienti RM, Huber SJ, et al. (2003). Genitourinary applications of sacral neuromodulation. W V Med J.
1027 Johnstone JM, Ardran GM, Ramsden PD. (1977). A preliminary assessment of bladder distension in the treatment of enuretic children. Br J Urol.
1028 Jolleys JV. (1988). Reported prevalence of urinary incontinence in women in a general practice. Br Med J (Clin Res Ed).
1029 Jolleys JV. (1989). Diagnosis and management of female urinary incontinence in general practice. J R Coll Gen Pract.
1030 Jones JS, Rackley RR, Berglund R, et al. (2005). Porcine small intestinal submucosa as a percutaneous mid-urethral sling: 2-year results. BJU Int.
1031 Jorgensen L, Lose G, Molsted-Pedersen L. (1987). Vaginal repair in female motor urge incontinence. Eur Urol.
1032 Jorgensen L, Mortensen SO, Colstrup H, et al. (1985). Bladder distension in the management of detrusor instability. Scand J Urol Nephrol.
1033 Jose CC, Price A, Norman A, et al. (1999). Hypofractionated radiotherapy for patients with carcinoma of the bladder. Clin Oncol (R Coll Radiol).
1034 Jozwik M, Jozwik M, Lotocki W. (1998). Stress urinary incontinence in women. III. Different tissue biochemistry in patients with concomitant detrusor instability. Preliminary report. Int Urol Nephrol.
1035 Juma S. (1995). Anterior vaginal suspension for vaginal vault prolapse. Tech Urol.
1036 Juma S, Brito CG. (2007). Transobturator tape (TOT): Two years follow-up. Neurourol Urodyn.
1037 Juma S, Little NA, Raz S. (1992). Vaginal wall sling: four years later. Urology.
1038 Jumadilova Z, Varadharajan S, Girase P, et al. (2006). Retrospective evaluation of outcomes in patients with overactive bladder receiving tolterodine versus oxybutynin. Am J Health Syst Pharm.
1039 Jundt K, Scheer I, Schiessl B, et al. (2007). Physical and sexual abuse in patients with overactive bladder: is there an association?. Int Urogynecol J Pelvic Floor Dysfunct.
1040 Junemann KP, Halaska M, Rittstein T, et al. (2005). Propiverine versus tolterodine: efficacy and tolerability in patients with overactive bladder. Eur Urol.
1041 Junemann KP, Hessdorfer E, Unamba-Oparah I, et al. (2006). Propiverine hydrochloride immediate and extended release: comparison of efficacy and tolerability in patients with overactive bladder. Urol Int.
1042 Kaat LD, Boon AJ, Kamphorst W, et al. (2007). Frontal presentation in progressive supranuclear palsy. Neurology.
1043 Kabay SC, Kabay S, Yucel M, et al. (2009). Acute urodynamic effects of percutaneous posterior tibial nerve stimulation on neurogenic detrusor overactivity in patients with Parkinson’s disease. Neurourol Urodyn.
1044 Kabay SC, Yucel M, Kabay S. (2008). Acute effect of posterior tibial nerve stimulation on neurogenic detrusor overactivity in patients with multiple sclerosis: urodynamic study. Urology.
1045 Kadar N. (1988). The value of bladder filling in the clinical detection of urine loss and selection of patients for urodynamic testing. Br J Obstet Gynaecol.
1046 Kafri R, Langer R, Dvir Z, et al. (2007). Rehabilitation vs drug therapy for urge urinary incontinence: short-term outcome. Int Urogynecol J Pelvic Floor Dysfunct.
1047 Kafri R, Shames J, Raz M, et al. (2008). Rehabilitation versus drug therapy for urge urinary incontinence: long-term outcomes. Int Urogynecol J Pelvic Floor Dysfunct.
1048 Kagan G. (1970). Emepronium bromide in the management of nightly urinary frequency and urinary incontinence. Practitioner.
1049 Kajiwara M, Inoue K, Kato M, et al. (2006). Nocturnal enuresis and overactive bladder in children: an epidemiological study. Int J Urol.
1050 Kajiwara M, Inoue K, Mutaguchi K, et al. (2006). The prevalence of overactive bladder and nocturnal enuresis in Japanese early adolescents: a questionnaire survey. Hinyokika Kiyo.
1051 Kajiwara M, Kato M, Mutaguchi K, et al. (2008). Overactive bladder in children should be strictly differentiated from monosymptomatic nocturnal enuresis. Urol Int.
1052 Kajiwara M, Mutaguchi K. (2008). Clinical efficacy and tolerability of gosha-jinki-gan, Japanese traditional herbal medicine, in females with overactive bladder. Hinyokika Kiyo.
1053 Kalita J, Shah S, Kapoor R, et al. (2002). Bladder dysfunction in acute transverse myelitis: magnetic resonance imaging and neurophysiological and urodynamic correlations. J Neurol Neurosurg Psychiatry.
1054 Kallestrup EB, Jorgensen SS, Nordling J, et al. (2005). Treatment of interstitial cystitis with Cystistat: a hyaluronic acid product. Scand J Urol Nephrol.
1055 Kalsi V, Apostolidis A, Gonzales G, et al. (2008). Early effect on the overactive bladder symptoms following botulinum neurotoxin type A injections for detrusor overactivity. Eur Urol.
1056 Kalsi V, Apostolidis A, Popat R, et al. (2006). Quality of life changes in patients with neurogenic versus idiopathic detrusor overactivity after intradetrusor injections of botulinum neurotoxin type A and correlations with lower urinary tract symptoms and urodynamic changes. Eur Urol.
1057 Kalsi V, Gonzales G, Popat R, et al. (2007). Botulinum injections for the treatment of bladder symptoms of multiple sclerosis. Ann Neurol.
1058 Kalsi V, Popat RB, Apostolidis A, et al. (2006). Cost-consequence analysis evaluating the use of botulinum neurotoxin-A in patients with detrusor overactivity based on clinical outcomes observed at a single UK centre. Eur Urol.
1059 Kamm MA, Hawley PR, Lennard-Jones JE. (1988). Lateral division of the puborectalis muscle in the management of severe constipation. Br J Surg.
1060 Kanayama N, Kanari C, Masuda Y, et al. (2007). Drug-drug interactions in the metabolism of imidafenacin: role of the human cytochrome P450 enzymes and UDP-glucuronic acid transferases, and potential of imidafenacin to inhibit human cytochrome P450 enzymes. Xenobiotica.
1061 Kang HS, Wang KC, Kim KM, et al. (2006). Prognostic factors affecting urologic outcome after untethering surgery for lumbosacral lipoma. Childs Nerv Syst.
1062 Kaplan HJ, Mamo GJ. (2000). Pubovaginal sling technique utilizing a unique bone anchor instrumentation system. Can J Urol.
1063 Kaplan SA, Santarosa RP, Te AE. (1996). Comparison of fascial and vaginal wall slings in the management of intrinsic sphincter deficiency. Urology.
1064 Kaplan SA, Te AE, Young GP, et al. (2000). Prospective analysis of 373 consecutive women with stress urinary incontinence treated with a vaginal wall sling: the Columbia-Cornell University experience. J Urol.
1065 Karademir K, Baykal K, Sen B, et al. (2005). A peripheric neuromodulation technique for curing detrusor overactivity: Stoller afferent neurostimulation. Scand J Urol Nephrol.
1066 Karaman MI, Kaya C, Caskurlu T, et al. (2005). Urodynamic findings in children with cerebral palsy. Int J Urol.
1067 Karantanis E, Fynes MM, Stanton SL. (2004). The tension-free vaginal tape in older women. BJOG.
1068 Karon S. (2005). A team approach to bladder retraining: a pilot study. Urol Nurs.
1069 Karram MM, Bhatia NN. (1989). Management of coexistent stress and urge urinary incontinence. Obstet Gynecol.
1070 Karram MM, Segal JL, Vassallo BJ, et al. (2003). Complications and untoward effects of the tension-free vaginal tape procedure. Obstet Gynecol.
1071 Karsenty G, Chartier-Kastler E, Mozer P, et al. (2008). A novel technique to achieve cutaneous continent urinary diversion in spinal cord-injured patients unable to catheterize through native urethra. Spinal Cord.
1072 Karsenty G, Elzayat E, Delapparent T, et al. (2007). Botulinum toxin type a injections into the trigone to treat idiopathic overactive bladder do not induce vesicoureteral reflux. J Urol.
1073 Kasirga E, Akil I, Yilmaz O, et al. (2006). Evaluation of voiding dysfunctions in children with chronic functional constipation. Turk J Pediatr.
1074 Kato K, Furuhashi K, Suzuki K, et al. (2007). Overactive bladder and glaucoma: a survey at outpatient clinics in Japan. Int J Urol.
1075 Kaufman JM. (1979). Urodynamics in stress urinary incontinence. J Urol.
1076 Kauppila A, Alavaikko P, Kujansuu E. (1982). Detrusor instability score in the evaluation of stress urinary incontinence. Acta Obstet Gynecol Scand.
1077 Kavallaris A, Kohler C, Diebolder H, et al. (2005). Repair of prolapse with vaginal sacrocolporectopexy: technique and results. Eur J Obstet Gynecol Reprod Biol.
1078 Kawabe K, Abe S, Kanda T, et al. (1986). Clinical reevaluation of the effect of oxybutynin chloride on uninhibited neurogenic and reflex neurogenic bladder. Urol Int.
1079 Kay G, Crook T, Rekeda L, et al. (2006). Differential effects of the antimuscarinic agents darifenacin and oxybutynin ER on memory in older subjects. Eur Urol.
1080 Kaya C, Ilktac A, Gunes M, et al. (2008). The efficacy of trospium chloride in women with an overactive bladder. Marmara Medical Journal.
1081 Kaya H, Sezik M, Ozbasar D, et al. (2004). Intrafascial versus extrafascial abdominal hysterectomy: effects on urinary urge incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
1082 Kayigil O, Atahan O, Metin A. (1998). Experiences with clam ileocystoplasty. Int Urol Nephrol.
1083 Kayigil O, Aytac B, Cakar KS, et al. (2001). Clam ileocystoplasty in adult nocturnal enuresis. Int Urol Nephrol.
1084 Kayigil O, Metin A, Atmaca AF. (2007). Obstructive urodynamic findings in idiopathic detrusor overactivity. Int Urol Nephrol.
1085 Kebapci N, Yenilmez A, Efe B, et al. (2007). Bladder dysfunction in type 2 diabetic patients. Neurourol Urodyn.
1086 Keeler JR, Hurst CG, Dunn MA. (1991). Pyridostigmine used as a nerve agent pretreatment under wartime conditions. JAMA.
1087 Kelleher C, Cardozo L, Kobashi K, et al. (2006). Solifenacin: as effective in mixed urinary incontinence as in urge urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
1088 Kelleher CJ, Cardozo LD, Khullar V, et al. (1997). A medium-term analysis of the subjective efficacy of treatment for women with detrusor instability and low bladder compliance. Br J Obstet Gynaecol.
1089 Kelleher CJ, Cardozo LD, Khullar V, et al. (1997). A new questionnaire to assess the quality of life of urinary incontinent women. Br J Obstet Gynaecol.
1090 Kelleher CJ, Pleil AM, Reese PR, et al. (2004). How much is enough and who says so?. BJOG.
1091 Kelleher CJ, Tubaro A, Wang JT, et al. (2008). Impact of fesoterodine on quality of life: pooled data from two randomized trials. BJU Int.
1092 Kelly JD, Kernohan RM, Keane PF. (1997). Symptomatic outcome following clam ileocystoplasty. Eur Urol.
1093 Kempton CL, Kurtin PJ, Inwards DJ, et al. (1997). Malignant lymphoma of the bladder: evidence from 36 cases that low-grade lymphoma of the MALT-type is the most common primary bladder lymphoma. Am J Surg Pathol.
1094 Kendall AR, Stein BS. (1983). Practical approach to stress urinary incontinence. Geriatrics.
1095 Kennelly MJ, Kang J. (2003). Botulinum-A toxin injections as a treatment for refractory detrusor hyperreflexia. Topics in Spinal Cord Injury Rehabilitation.
1096 Kenton K, Brubaker L. (2002). Relationship between levator ani contraction and motor unit activation in the urethral sphincter. Am J Obstet Gynecol.
1097 Kenton K, Fitzgerald MP, Brubaker L. (2006). What is a clinician to do-believe the patient or her urinary diary?. J Urol.
1098 Kenton K, FitzGerald MP, Shott S, et al. (2001). Role of urethral electromyography in predicting outcome of Burch retropubic urethropexy. Am J Obstet Gynecol.
1099 Kenton K, Lowenstein L, Simmons J, et al. (2007). Aging and overactive bladder may be associated with loss of urethral sensation in women. Neurourol Urodyn.
1100 Kenton K, Oldham L, Brubaker L. (2002). Open Burch urethropexy has a low rate of perioperative complications. Am J Obstet Gynecol.
1101 Kersey J, Martin MR, Mishra P. (1988). A further assessment of the gauze hammock sling operation in the treatment of stress incontinence. Br J Obstet Gynaecol.
1102 Kessler R, Constantinou CE. (1986). Internal urethrotomy in girls and its impact on the urethral intrinsic and extrinsic continence mechanisms. J Urol.
1103 Kessler TM, Burkhard FC, Madersbacher H, et al. (2008). Safety of prolonged sacral neuromodulation tined lead testing. Curr Med Res Opin.
1104 Kessler TM, Burkhard FC, Z’Brun S, et al. (2008). Effect of thalamic deep brain stimulation on lower urinary tract function. Eur Urol.
1105 Kessler TM, Danuser H, Schumacher M, et al. (2005). Botulinum A toxin injections into the detrusor: an effective treatment in idiopathic and neurogenic detrusor overactivity?. Neurourol Urodyn.
1106 Kessler TM, Lackner J, Kiss G, et al. (2006). Predictive value of initial urodynamic pattern on urinary continence in patients with myelomeningocele. Neurourol Urodyn.
1107 Kessler TM, Madersbacher H, Kiss G. (2005). Prolonged sacral neuromodulation testing using permanent leads: a more reliable patient selection method?. Eur Urol.
1108 Khan Z, Starer P, Bhola A. (1989). Urinary incontinence in female Parkinson disease patients. Pitfalls of diagnosis. Urology.
1109 Khan Z, Starer P, Singh VK, et al. (1993). Role of detrusor instability in primary enuresis. Urology.
1110 Khoury AE, Dave S, Peralta-Del Valle MH, et al. (2008). Severe bladder trabeculation obviates the need for bladder outlet procedures during augmentation cystoplasty in incontinent patients with neurogenic bladder. BJU Int.
1111 Khullar V, Cardozo LD, Salvatore S, et al. (1996). Ultrasound: a noninvasive screening test for detrusor instability. Br J Obstet Gynaecol.
1112 Khullar V, Damiano R, Toozs-Hobson P, et al. (1998). Prevalence of faecal incontinence among women with urinary incontinence. Br J Obstet Gynaecol.
1113 Khullar V, Hill S, Laval KU, et al. (2004). Treatment of urge-predominant mixed urinary incontinence with tolterodine extended release: a randomized, placebo-controlled trial. Urology.
1114 Khullar V, Rovner ES, Dmochowski R, et al. (2008). Fesoterodine dose response in subjects with overactive bladder syndrome. Urology.
1115 Kibar Y, Demir E, Irkilata C, et al. (2007). Effect of biofeedback treatment on spinning top urethra in children with voiding dysfunction. Urology.
1116 Kilic N, Balkan E, Akgoz S, et al. (2006). Comparison of the effectiveness and side-effects of tolterodine and oxybutynin in children with detrusor instability. Int J Urol.
1117 Kim HL, Gerber GS, Patel RV, et al. (2001). Practice patterns in the treatment of female urinary incontinence: a postal and internet survey. Urology.
1118 Kim JC, Park EY, Seo SI, et al. (2006). Nerve growth factor and prostaglandins in the urine of female patients with overactive bladder. J Urol.
1119 Kim JW, Kim MJ, Noh JY, et al. (2005). Extracorporeal pelvic floor magnetic stimulation in children with voiding dysfunction. BJU Int.
1120 Kim MD, Won JW, Lee DY, et al. (2004). Uterine artery embolization for adenomyosis without fibroids. Clin Radiol.
1121 Kim SW, Song SH, Ku JH. (2008). Bladder training versus combination of propiverine with bladder training for female urinary frequency. A prospective, randomized, comparative study. Gynecol Obstet Invest.
1122 Kim Y, Yoshimura N, Masuda H, et al. (2006). Intravesical instillation of human urine after oral administration of trospium, tolterodine and oxybutynin in a rat model of detrusor overactivity. BJU Int.
1123 Kim YH, Kattan MW, Boone TB. (1997). Correlation of urodynamic results and urethral coaptation with success after transurethral collagen injection. Urology.
1124 Kim YH, Seo JT, Yoon H. (2005). The effect of overactive bladder syndrome on the sexual quality of life in Korean young and middle aged women. Int J Impot Res.
1125 Kim YT, Kwon DD, Kim J, et al. (2004). Gabapentin for overactive bladder and nocturia after anticholinergic failure. Int Braz J Urol.
1126 Kinn AC, Nilsson BY. (2005). Urethral sensitivity in incontinent women. Eur Urol.
1127 Kjolhede P. (2005). Long-term efficacy of Burch colposuspension: a 14-year follow-up study. Acta Obstet Gynecol Scand.
1128 Kjolhede P, Ryden G. (1997). Clinical and urodynamic characteristics of women with recurrent urinary incontinence after Burch colposuspension. Acta Obstet Gynecol Scand.
1129 Kjolhede P, Wahlstrom J, Wingren G. (2005). Pelvic floor dysfunction after Burch colposuspension--a comprehensive study. Part I. Acta Obstet Gynecol Scand.
1130 Kjolseth D, Madsen B, Knudsen LM, et al. (1994). Biofeedback treatment of children and adults with idiopathic detrusor instability. Scand J Urol Nephrol.
1131 Klaphajone J, Kitisomprayoonkul W, Sriplakit S. (2005). Botulinum toxin type A injections for treating neurogenic detrusor overactivity combined with low-compliance bladder in patients with spinal cord lesions. Arch Phys Med Rehabil.
1132 Klarskov N, Lose G. (2007). Urethral pressure reflectometry vs urethral pressure profilometry in women: a comparative study of reproducibility and accuracy. BJU Int.
1133 Klarskov P, Gerstenberg TC, Hald T. (1986). Bladder training and terodiline in females with idiopathic urge incontinence and stable detrusor function. Scand J Urol Nephrol.
1134 Klausner AP, Sharma S, Fletcher S, et al. (2008). Does oxybutynin alter plaques, amyloid beta peptides and behavior in a mouse model of Alzheimer’s disease?. J Urol.
1135 Klay M, Marfyak K. (2005). Use of a continence nurse specialist in an extended care facility. Urol Nurs.
1136 Kleeman S, Vassallo B, Segal J, et al. (2006). The ability of history and a negative cough stress test to detect occult stress incontinence in patients undergoing surgical repair of advanced pelvic organ prolapse. Int Urogynecol J Pelvic Floor Dysfunct.
1137 Klein LA. (1987). Measurement of trigonal sensitivity as a test of bladder function. J Urol.
1138 Klevan JL, De Jong AR. (1990). Urinary tract symptoms and urinary tract infection following sexual abuse. Am J Dis Child.
1139 Klijn AJ, Uiterwaal CS, Vijverberg MA, et al. (2006). Home uroflowmetry biofeedback in behavioral training for dysfunctional voiding in school-age children: a randomized controlled study. J Urol.
1140 Klingele CJ, Carley ME, Hill RF. (2002). Patient characteristics that are associated with urodynamically diagnosed detrusor instability and genuine stress incontinence. Am J Obstet Gynecol.
1141 Klingler HC, Pycha A, Schmidbauer J, et al. (2000). Use of peripheral neuromodulation of the S3 region for treatment of detrusor overactivity: a urodynamic-based study. Urology.
1142 Klotz T, Bruggenjurgen B, Burkart M, et al. (2007). The economic costs of overactive bladder in Germany. Eur Urol.
1143 Klovning A, Hunskaar S, Eriksen BC. (1996). Validity of a scored urological history in detecting detrusor instability in female urinary incontinence. Acta Obstet Gynecol Scand.
1144 Klutke C, Siegel S, Carlin B, et al. (2001). Urinary retention after tension-free vaginal tape procedure: incidence and treatment. Urology.
1145 Klutke JJ, Bergman J, Klutke CG. (2000). Transvaginal bladder neck suspension with Cooper’s ligament fixation. Long-term urodynamic results. J Reprod Med.
1146 Klutke JJ, Ramos S. (2000). Urodynamic outcome after surgery for severe prolapse and potential stress incontinence. Am J Obstet Gynecol.
1147 Kobashi KC, Govier FE. (2003). Management of vaginal erosion of polypropylene mesh slings. J Urol.
1148 Kobashi KC, Leach GE, Chon J, et al. (2002). Continued multicenter followup of cadaveric prolapse repair with sling. J Urol.
1149 Kobashi KC, Mee SL, Leach GE. (2000). A new technique for cystocele repair and transvaginal sling: the cadaveric prolapse repair and sling (CAPS). Urology.
1150 Kobelt G. (1997). Economic considerations and outcome measurement in urge incontinence. Urology.
1151 Kochakarn W, Pummangura N, Kijvikai K, et al. (2005). Reliability of a Thai version of King’s Health Questionnaire in Thai females with overactive bladder symptoms. J Med Assoc Thai.
1152 Kockelbergh RC, Tan JB, Bates CP, et al. (1991). Clam enterocystoplasty in general urological practice. Br J Urol.
1153 Koduri S, Goldberg RP, Sand PK. (2000). Transvaginal therapy of genuine stress incontinence. Urology.
1154 Koefoot RB, Webster GD. (1983). Urodynamic evaluation in women with frequency, urgency symptoms. Urology.
1155 Koelbl H, Bernaschek G. (1989). A new method for sonographic urethrocystography and simultaneous pressure-flow measurements. Obstet Gynecol.
1156 Koelbl H, Bernaschek G, Deutinger J. (1990). Assessment of female urinary incontinence by introital sonography. J Clin Ultrasound.
1157 Koh CJ, DeFilippo RE, Borer JG, et al. (2006). Bladder and external urethral sphincter function after prenatal closure of myelomeningocele. J Urol.
1158 Kok AL, Burger CW, van de Weijer PH, et al. (1999). Micturition complaints in postmenopausal women treated with continuously combined hormone replacement therapy: a prospective study. Maturitas.
1159 Komine S, Yoshida H, Fujiyama C, et al. (1991). Voiding dysfunction in patients with human T-lymphotropic-virus-type-1-associated myelopathy. Urol Int.
1160 Komine S, Yoshida K, Yamashita H, et al. (1989). Voiding dysfunction in patients with human T-lymphotropic virus type-1-associated myelopathy (HAM). Paraplegia.
1161 Kondo A, Isobe Y, Kimura K, et al. (2006). Efficacy, safety and hospital costs of tension-free vaginal tape and pubovaginal sling in the surgical treatment of stress incontinence. J Obstet Gynaecol Res.
1162 Kondo A, Kobayashi M, Otani T, et al. (1983). Children with unstable bladder: clinical and urodynamic observation. J Urol.
1163 Kondo Y, Homma Y, Takahashi S, et al. (2001). Transvaginal ultrasound of urethral sphincter at the mid urethra in continent and incontinent women. J Urol.
1164 Kong KH, Chan KF, Lim AC, et al. (1994). Detrusor hyperreflexia in strokes. Ann Acad Med Singapore.
1165 Kontturi MJ, Hellstrom PA, Tammela TL, et al. (1991). Colocystoplasty for the treatment of severe interstitial cystitis. Urol Int.
1166 Koonings P, Bergman A, Ballard CA. (1988). Combined detrusor instability and stress urinary incontinence: where is the primary pathology?. Gynecol Obstet Invest.
1167 Kopp JB, Miller KD, Mican JA, et al. (1997). Crystalluria and urinary tract abnormalities associated with indinavir. Ann Intern Med.
1168 Korda A, Cooper M, Hunter P. (1989). Coital urinary incontinence in an Australian population. Asia Oceania J Obstet Gynaecol.
1169 Korda A, Ferry J, Hunter P. (1989). Colposuspension for the treatment of female urinary incontinence. Aust N Z J Obstet Gynaecol.
1170 Korda A, Peat B, Hunter P. (1989). Experience with silastic slings for female urinary incontinence. Aust N Z J Obstet Gynaecol.
1171 Kowalczyk JJ. (2000). Office evaluation of the patient with an overactive urinary bladder. J Am Osteopath Assoc.
1172 Krauwinkel WJ, Smulders RA, Mulder H, et al. (2005). Effect of age on the pharmacokinetics of solifenacin in men and women. Int J Clin Pharmacol Ther.
1173 Krogh RA, Neumann GA, Lauszus FF, et al. (2007). Hysterectomy is associated with stress incontinence in women who previously had a transcervical endometrial resection. Gynecol Obstet Invest.
1174 Krue S, Jensen H, Agger AO, et al. (1997). The influence of infant birth weight on post partum stress incontinence in obese women. Arch Gynecol Obstet.
1175 Ku JH, Oh JG, Shin JW, et al. (2006). Age is not a limiting factor for midurethral sling procedures in the elderly with urinary incontinence. Gynecol Obstet Invest.
1176 Kuhn A, Hiltebrand R, Birkhauser M. (2007). Do transsexuals have micturition disorders?. Eur J Obstet Gynecol Reprod Biol.
1177 Kuhn A, Vits K, Kuhn P, et al. (2006). Do women with urinary incontinence really know where all the toilets are? The toilet paper. Eur J Obstet Gynecol Reprod Biol.
1178 Kuipers M, Smulders R, Krauwinkel W, et al. (2006). Open-label study of the safety and pharmacokinetics of solifenacin in subjects with hepatic impairment. J Pharmacol Sci.
1179 Kulseng-Hanssen S. (1983). Prevalence and pattern of unstable urethral pressure in one hundred seventy-four gynecologic patients referred for urodynamic investigation. Am J Obstet Gynecol.
1180 Kulseng-Hanssen S. (2003). The development of a national database of the results of surgery for urinary incontinence in women. BJOG.
1181 Kulseng-Hanssen S, Borstad E. (2003). The development of a questionnaire to measure the severity of symptoms and the quality of life before and after surgery for stress incontinence. BJOG.
1182 Kulseng-Hanssen S, Husby H, Schiotz HA. (2007). The tension free vaginal tape operation for women with mixed incontinence: Do preoperative variables predict the outcome?. Neurourol Urodyn.
1183 Kulseng-Hanssen S, Husby H, Schiotz HA. (2008). Follow-up of TVT operations in 1, 113 women with mixed urinary incontinence at 7 and 38 months. Int Urogynecol J Pelvic Floor Dysfunct.
1184 Kulseng-Hanssen S, Kristoffersen M, Larsen E. (1998). Evaluation of the subjective and objective effect of maximal electrical stimulation in patients complaining of urge incontinence. Acta Obstet Gynecol Scand Suppl.
1185 Kumar SP, Abrams PH. (2005). Detrusor myectomy: long-term results with a minimum follow-up of 2 years. BJU Int.
1186 Kunkle JC, Payne CK, Whitmore KE. (1993). Urinary incontinence: combined biofeedback and electrical stimulation treatment. Journal of Urological Nursing.
1187 Kuo HC. (1999). Videourodynamic results after pubovaginal sling procedure for stress urinary incontinence. Urology.
1188 Kuo HC. (2000). Videourodynamic study for diagnosis of bladder outlet obstruction in women. J Formos Med Assoc.
1189 Kuo HC. (2001). Anatomical and functional results of pubovaginal sling procedure using polypropylene mesh for the treatment of stress urinary incontinence. J Urol.
1190 Kuo HC. (2001). Comparison of video urodynamic results after the pubovaginal sling procedure using rectus fascia and polypropylene mesh for stress urinary incontinence. J Urol.
1191 Kuo HC. (2001). Sonographic evaluation of anatomic results after the pubovaginal sling procedure for stress urinary incontinence. J Ultrasound Med.
1192 Kuo HC. (2002). Efficacy of desmopressin in treatment of refractory nocturia in patients older than 65 years. Urology.
1193 Kuo HC. (2003). Effectiveness of intravesical resiniferatoxin for anticholinergic treatment refractory detrusor overactivity due to nonspinal cord lesions. J Urol.
1194 Kuo HC. (2003). Videourodynamic results in stress urinary incontinence patients after pelvic floor muscle training. J Formos Med Assoc.
1195 Kuo HC. (2004). Urodynamic evidence of effectiveness of botulinum A toxin injection in treatment of detrusor overactivity refractory to anticholinergic agents. Urology.
1196 Kuo HC. (2005). Clinical effects of suburothelial injection of botulinum A toxin on patients with nonneurogenic detrusor overactivity refractory to anticholinergics. Urology.
1197 Kuo HC. (2005). Long-term surgical results of pubovaginal sling procedure using polypropylene mesh in the treatment of stress urinary incontinence. Urol Int.
1198 Kuo HC. (2005). Preliminary results of suburothelial injection of botulinum a toxin in the treatment of chronic interstitial cystitis. Urol Int.
1199 Kuo HC. (2005). Videourodynamic characteristics and lower urinary tract symptoms of female bladder outlet obstruction. Urology.
1200 Kuo HC. (2006). Therapeutic effects of suburothelial injection of botulinum a toxin for neurogenic detrusor overactivity due to chronic cerebrovascular accident and spinal cord lesions. Urology.
1201 Kuo HC. (2006). Will suburothelial injection of small dose of botulinum A toxin have similar therapeutic effects and less adverse events for refractory detrusor overactivity?. Urology.
1202 Kuo HC. (2007). Comparison of effectiveness of detrusor, suburothelial and bladder base injections of botulinum toxin a for idiopathic detrusor overactivity. J Urol.
1203 Kuo HC. (2007). Effect of detrusor function on the therapeutic outcome of a suburethral sling procedure using a polypropylene sling for stress urinary incontinence in women. Scand J Urol Nephrol.
1204 Kuo HC. (2008). Therapeutic satisfaction and dissatisfaction in patients with spinal cord lesions and detrusor sphincter dyssynergia who received detrusor botulinum toxin a injection. Urology.
1205 Kuo HC, Liu HT. (2006). Investigation of dysfunctional voiding in children with urgency frequency syndrome and urinary incontinence. Urol Int.
1206 Kuo HC, Liu HT, Yang WC. (2006). Therapeutic effect of multiple resiniferatoxin intravesical instillations in patients with refractory detrusor overactivity: a randomized, double-blind, placebo controlled study. J Urol.
1207 Kupelian V, Rosen RC, Link CL, et al. (2009). Association of urological symptoms and chronic illness in men and women: contributions of symptom severity and duration--results from the BACH Survey. J Urol.
1208 Kuriyama N, Tokuda T, Kondo M, et al. (2008). Evaluation of autonomic malfunction in idiopathic normal pressure hydrocephalus. Clin Auton Res.
1209 Kurstjens GA, Borau A, Rodriguez A, et al. (2005). Intraoperative recording of electroneurographic signals from cuff electrodes on extradural sacral roots in spinal cord injured patients. J Urol.
1210 Kurstjens M, Rijkhoff NJ, Borau A, et al. (2005). Intraoperative recording of sacral root nerve signals in humans. Artif Organs.
1211 Kuruba R, Almahmeed T, Martinez F, et al. (2007). Bariatric surgery improves urinary incontinence in morbidly obese individuals. Surg Obes Relat Dis.
1212 Kuschel S, Werner M, Schmid DM, et al. (2008). Botulinum toxin-A for idiopathic overactivity of the vesical detrusor: a 2-year follow-up. Int Urogynecol J Pelvic Floor Dysfunct.
1213 Kushner L, Chiu PY, Brettschneider N, et al. (2001). Urinary substance P concentration correlates with urinary frequency and urgency in interstitial cystitis patients treated with intravesical dimethyl sulfoxide and not intravesical anesthetic cocktail. Urology.
1214 Kutzenberger J. (2007). Surgical therapy of neurogenic detrusor overactivity (hyperreflexia) in paraplegic patients by sacral deafferentation and implant driven micturition by sacral anterior root stimulation: methods, indications, results, complications, and future prospects. Acta Neurochir Suppl.
1215 Kuuva N, Nilsson CG. (2003). Tension-free vaginal tape procedure: an effective minimally invasive operation for the treatment of recurrent stress urinary incontinence?. Gynecol Obstet Invest.
1216 Kwak KW, Park KH. (2008). Clinical inconsistency of lower urinary tract symptoms between questionnaire and bladder diary in children with nocturnal enuresis. J Urol.
1217 Lackner TE, Wyman JF, McCarthy TC, et al. (2008). Randomized, placebo-controlled trial of the cognitive effect, safety, and tolerability of oral extended-release oxybutynin in cognitively impaired nursing home residents with urge urinary incontinence. J Am Geriatr Soc.
1218 Lagro-Janssen AL, Debruyne FM, Smits AJ, et al. (1992). The effects of treatment of urinary incontinence in general practice. Fam Pract.
1219 Lagro-Janssen AL, Debruyne FM, van Weel C. (1991). Value of the patient’s case history in diagnosing urinary incontinence in general practice. Br J Urol.
1220 Lagro-Janssen AL, Debruyne FM, Van Weel C. (1992). Psychological aspects of female urinary incontinence in general practice. Br J Urol.
1221 Lagro-Janssen T, Smits A, Van Weel C. (1992). Urinary incontinence in women and the effects on their lives. Scand J Prim Health Care.
1222 Lagro-Janssen T, van Weel C. (1998). Long-term effect of treatment of female incontinence in general practice. Br J Gen Pract.
1223 Lajer H, Thranov IR, Bagi P, et al. (2002). Evaluation of urologic morbidity after radiotherapy for cervical carcinoma by urodynamic examinations and patient voiding schemes: a prospective study. Int J Radiat Oncol Biol Phys.
1224 Lalos O, Berglund AL, Lalos A. (2001). Impact of urinary and climacteric symptoms on social and sexual life after surgical treatment of stress urinary incontinence in women: a long-term outcome. J Adv Nurs.
1225 Lalos O, Bjerle P. (1986). Bladder wall mechanics and micturition before and after subtotal and total hysterectomy. Eur J Obstet Gynecol Reprod Biol.
1226 Lammers RL, Gibson S, Kovacs D, et al. (2001). Comparison of test characteristics of urine dipstick and urinalysis at various test cutoff points. Ann Emerg Med.
1227 Lang EW, Chesnut RM, Hennerici M. (1996). Urinary retention and space-occupying lesions of the frontal cortex. Eur Neurol.
1228 Langer R, Golan A, Arad D, et al. (1992). Effects of induced menopause on Burch colposuspension for urinary stress incontinence. J Reprod Med.
1229 Langer R, Golan A, Neuman M, et al. (1990). The effect of large uterine fibroids on urinary bladder function and symptoms. Am J Obstet Gynecol.
1230 Langer R, Golan A, Ron-El R, et al. (1990). Colposuspension for urinary stress incontinence in premenopausal and postmenopausal women. Surg Gynecol Obstet.
1231 Langer R, Lipshitz Y, Halperin R, et al. (2001). Long-Term (10–15 years) follow-up after Burch colposuspension for urinary stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
1232 Langer R, Ron-El R, Bukovsky I, et al. (1988). Colposuspension in patients with combined stress incontinence and detrusor instability. Eur Urol.
1233 Langer R, Ron-el R, Newman M, et al. (1988). Detrusor instability following colposuspension for urinary stress incontinence. Br J Obstet Gynaecol.
1234 Lapitan MC, Chye PL. (2001). The epidemiology of overactive bladder among females in Asia: a questionnaire survey. Int Urogynecol J Pelvic Floor Dysfunct.
1235 Larsson G, Hallen B, Nilvebrant L. (1999). Tolterodine in the treatment of overactive bladder: analysis of the pooled phase II efficacy and safety data. Urology.
1236 Latini JM, Alipour M, Kreder KJ. (2006). Efficacy of sacral neuromodulation for symptomatic treatment of refractory urinary urge incontinence. Urology.
1237 Lau DT, Morlock RJ, Hill CD. (2006). Psychometric evaluation of the medical outcomes study-sleep scale in persons with overactive bladder. Clin Ther.
1238 Laurikainen E, Kiilholma P. (2003). The tension-free vaginal tape procedure for female urinary incontinence without preoperative urodynamic evaluation. J Am Coll Surg.
1239 Laurikainen E, Rosti J, Pitkanen Y, et al. (2004). The Rosti sling: a new, minimally invasive, tension-free technique for the surgical treatment of female urinary incontinence-the first 217 patients. J Urol.
1240 Laurikainen E, Valpas A, Kivela A, et al. (2007). Retropubic compared with transobturator tape placement in treatment of urinary incontinence: a randomized controlled trial. Obstet Gynecol.
1241 Laurikkala J, Juhola M. (1998). A genetic-based machine learning system to discover the diagnostic rules for female urinary incontinence. Comput Methods Programs Biomed.
1242 Lawrence M, Guay DR, Benson SR, et al. (2000). Immediate-release oxybutynin versus tolterodine in detrusor overactivity: a population analysis. Pharmacotherapy.
1243 Lawton V, Smith AR. (1999). Laparoscopic colposuspension. Semin Laparosc Surg.
1244 Lazzeri M, Beneforti P, Turini D. (1997). Urodynamic effects of intravesical resiniferatoxin in humans: preliminary results in stable and unstable detrusor. J Urol.
1245 Lazzeri M, Calo G, Spinelli M, et al. (2003). Urodynamic effects of intravesical nociceptin/orphanin FQ in neurogenic detrusor overactivity: a randomized, placebo-controlled, double-blind study. Urology.
1246 Lazzeri M, Calo G, Spinelli M, et al. (2006). Daily intravesical instillation of 1 mg nociceptin/orphanin FQ for the control of neurogenic detrusor overactivity: a multicenter, placebo controlled, randomized exploratory study. J Urol.
1247 Learman LA, Summitt RL, Varner RE, et al. (2004). Hysterectomy versus expanded medical treatment for abnormal uterine bleeding: clinical outcomes in the medicine or surgery trial. Obstet Gynecol.
1248 Leboeuf L, Miles RA, Kim SS, et al. (2004). Grade 4 cystocele repair using four-defect repair and porcine xenograft acellular matrix (Pelvicol): outcome measures using SEAPI. Urology.
1249 Lee HC, Liu CS, Chiao C, et al. (1994). Hyperbaric oxygen therapy in hemorrhagic radiation cystitis: a report of 20 cases. Undersea Hyperb Med.
1250 Lee JC, Yokoyama T, Hwang HJ, et al. (2007). Clinical application of Clostridium botulinum type A neurotoxin purified by a simple procedure for patients with urinary incontinence caused by refractory destrusor overactivity. FEMS Immunol Med Microbiol.
1251 Lee KA, DeJoseph JF. (1992). Sleep disturbances, vitality, and fatigue among a select group of employed childbearing women. Birth.
1252 Lee KS, Chan CJ, Merriman A, et al. (1991). Clinical profile of elderly urinary incontinence in Singapore: a community-based study. Ann Acad Med Singapore.
1253 Lee KS, Han DH, Choi YS, et al. (2007). A prospective trial comparing tension-free vaginal tape and transobturator vaginal tape inside-out for the surgical treatment of female stress urinary incontinence: 1-year followup. J Urol.
1254 Lee PE, Kung RC, Drutz HP. (2001). Periurethral autologous fat injection as treatment for female stress urinary incontinence: a randomized double-blind controlled trial. J Urol.
1255 Lee SS, Liu YC, Wann SR, et al. (1999). Once daily isepamicin treatment in complicated urinary tract infections. J Microbiol Immunol Infect.
1256 Lee WC, Wu HP, Tai TY, et al. (2009). Investigation of urodynamic characteristics and bladder sensory function in the early stages of diabetic bladder dysfunction in women with type 2 diabetes. J Urol.
1257 Lehtoranta K, Tainio H, Lukkari-Lax E, et al. (2002). Pharmacokinetics, efficacy, and safety of intravesical formulation of oxybutynin in patients with detrusor overactivity. Scand J Urol Nephrol.
1258 Leibovici D, Cooper A, Lindner A, et al. (2005). Ureteral stents: morbidity and impact on quality of life. Isr Med Assoc J.
1259 Leiby BE, Landis JR, Propert KJ, et al. (2007). Discovery of morphological subgroups that correlate with severity of symptoms in interstitial cystitis: a proposed biopsy classification system. J Urol.
1260 Lekka E, Lee LK. (2006). Successful treatment with intradetrusor Botulinum-A toxin for urethral urinary leakage (catheter bypassing) in patients with end-staged multiple sclerosis and indwelling suprapubic catheters. Eur Urol.
1261 Lekskulchai O, Dietz HP. (2007). Normal values for detrusor wall thickness in nulligravid women. Australian & New Zealand Continence Journal.
1262 Lekskulchai O, Dietz HP. (2008). Detrusor wall thickness as a test for detrusor overactivity in women. Ultrasound Obstet Gynecol.
1263 Lemack GE. (1999). Reversing the tide: emerging options for treating overactive bladder symptoms in women. Tex Med.
1264 Lemack GE. (2002). Management and treatment of overactive bladder in the older female patient. Clinical Geriatrics.
1265 Lemack GE, Frohman E, Ramnarayan P. (2007). Women with voiding dysfunction secondary to bladder outlet dyssynergia in the setting of multiple sclerosis do not demonstrate significantly elevated intravesical pressures. Urology.
1266 Lemack GE, Frohman EM, Zimmern PE, et al. (2006). Urodynamic distinctions between idiopathic detrusor overactivity and detrusor overactivity secondary to multiple sclerosis. Urology.
1267 Lemack GE, Hawker K, Frohman E. (2005). Incidence of upper tract abnormalities in patients with neurovesical dysfunction secondary to multiple sclerosis: analysis of risk factors at initial urologic evaluation. Urology.
1268 Lemack GE, Xu Y, Brubaker L, et al. (2007). Clinical and demographic factors associated with valsalva leak point pressure among women undergoing burch bladder neck suspension or autologous rectus fascial sling procedures. Neurourol Urodyn.
1269 Lemack GE, Zimmern PE. (1999). Predictability of urodynamic findings based on the Urogenital Distress Inventory-6 questionnaire. Urology.
1270 Lemack GE, Zimmern PE. (2000). Identifying patients who require urodynamic testing before surgery for stress incontinence based on questionnaire information and surgical history. Urology.
1271 Leng WW, Davies BJ, Tarin T, et al. (2004). Delayed treatment of bladder outlet obstruction after sling surgery: association with irreversible bladder dysfunction. J Urol.
1272 Lentz GM, Bavendam T, Stenchever MA, et al. (2002). Hormonal manipulation in women with chronic, cyclic irritable bladder symptoms and pelvic pain. Am J Obstet Gynecol.
1273 Leonardo CR, Filgueiras MF, Vasconcelos MM, et al. (2007). Risk factors for renal scarring in children and adolescents with lower urinary tract dysfunction. Pediatr Nephrol.
1274 Leppilahti M, Sairanen J, Tammela TL, et al. (2005). Prevalence of clinically confirmed interstitial cystitis in women: a population based study in Finland. J Urol.
1275 Leroi AM, Michot F, Grise P, et al. (2001). Effect of sacral nerve stimulation in patients with fecal and urinary incontinence. Dis Colon Rectum.
1276 Letourneau R, Sant GR, el-Mansoury M, et al. (1992). Activation of bladder mast cells in interstitial cystitis. Int J Tissue React.
1277 Lettgen B, von Gontard A, Olbing H, et al. (2002). Urge incontinence and voiding postponement in children: somatic and psychosocial factors. Acta Paediatr.
1278 Leung VY, Chu WC, Yeung CK, et al. (2006). Ureteric jet Doppler waveform and bladder wall thickness in children with nocturnal enuresis. Pediatr Res.
1279 LeVeque FG, Montgomery M, Potter D, et al. (1993). A multicenter, randomized, double-blind, placebo-controlled, dose-titration study of oral pilocarpine for treatment of radiation-induced xerostomia in head and neck cancer patients. J Clin Oncol.
1280 Levin I, Groutz A, Gold R, et al. (2004). Surgical complications and medium-term outcome results of tension-free vaginal tape: a prospective study of 313 consecutive patients. Neurourol Urodyn.
1281 Lev-Toaff AS, Karasick S, Toaff ME. (1993). Hysterosalpingography before and after myomectomy: clinical value and imaging findings. AJR Am J Roentgenol.
1282 Lewicky-Gaupp C, Cao DC, Culbertson S. (2008). Urinary and anal incontinence in African American teenaged gravidas during pregnancy and the puerperium. J Pediatr Adolesc Gynecol.
1283 Lewis JB, Ng AV, O’Connor RC, et al. (2007). Are there differences between women with urge predominant and stress predominant mixed urinary incontinence?. Neurourol Urodyn.
1284 Liang CC, Chang YL, Chang SD, et al. (2004). Pessary test to predict postoperative urinary incontinence in women undergoing hysterectomy for prolapse. Obstet Gynecol.
1285 Liang CC, Tseng LH, Horng SG, et al. (2007). Correlation of pelvic organ prolapse quantification system scores with obstetric parameters and lower urinary tract symptoms in primiparae postpartum. Int Urogynecol J Pelvic Floor Dysfunct.
1286 Liao KK, Chen JT, Lai KL, et al. (2008). Effect of sacral-root stimulation on the motor cortex in patients with idiopathic overactive bladder syndrome. Neurophysiol Clin.
1287 Liao YM, Dougherty MC, Biemer PP, et al. (2008). Factors related to lower urinary tract symptoms among a sample of employed women in Taipei. Neurourol Urodyn.
1288 Liapis A, Bakas P, Creatsas G. (2001). The efficacy of bladder distention therapy in the treatment of frequency and urgency. Eur J Obstet Gynecol Reprod Biol.
1289 Liapis A, Bakas P, Creatsas G. (2002). Burch colposuspension and tension-free vaginal tape in the management of stress urinary incontinence in women. Eur Urol.
1290 Liapis A, Bakas P, Creatsas G. (2007). Assessment of TVT efficacy in the management of patients with genuine stress incontinence with the use of epidural vs intravenous anesthesia. Int Urogynecol J Pelvic Floor Dysfunct.
1291 Liapis A, Bakas P, Creatsas G. (2008). Long-term efficacy of tension-free vaginal tape in the management of stress urinary incontinence in women: efficacy at 5- and 7-year follow-up. Int Urogynecol J Pelvic Floor Dysfunct.
1292 Liapis A, Bakas P, Pafiti A, et al. (2000). Changes in the quantity of collagen type I in women with genuine stress incontinence. Urol Res.
1293 Liatsikos EN, Gershbaum D, Kapoor R, et al. (2001). Comparison of symptoms related to positioning of double-pigtail stent in upper pole versus renal pelvis. J Endourol.
1294 Liberman JN, Hunt TL, Stewart WF, et al. (2001). Health-related quality of life among adults with symptoms of overactive bladder: results from a U.S. community-based survey. Urology.
1295 Lilly JD, Parsons CL. (1990). Bladder surface glycosaminoglycans is a human epithelial permeability barrier. Surg Gynecol Obstet.
1296 Lim J, Cornish A, Carey MP. (2006). Clinical and quality-of-life outcomes in women treated by the TVT-O procedure. BJOG.
1297 Lim JR, Bak CW, Lee JB. (2007). Comparison of anxiety between patients with mixed incontinence and those with stress urinary incontinence. Scand J Urol Nephrol.
1298 Lin AD, Lin AT, Chen KK, et al. (2004). Nocturnal enuresis in older adults. J Chin Med Assoc.
1299 Lin HH, Sheu BC, Lo MC, et al. (1998). Abnormal urodynamic findings after radical hysterectomy or pelvic irradiation for cervical cancer. Int J Gynaecol Obstet.
1300 Lin HH, Torng PL, Sheu BC, et al. (2003). Urodynamically age-specific prevalence of urinary incontinence in women with urinary symptoms. Neurourol Urodyn.
1301 Lin HH, Yu HJ, Sheu BC, et al. (2001). Importance of urodynamic study before radical hysterectomy for cervical cancer. Gynecol Oncol.
1302 Lin LY, Yeh NH, Lin CY, et al. (2004). Comparisons of urodynamic characteristics between female patients with overactive bladder and overactive bladder plus stress urinary incontinence. Urology.
1303 Lin TL, Ng SC, Chen YC, et al. (2005). What affects the occurrence of nocturia more: menopause or age?. Maturitas.
1304 Linder A, Leach GE, Raz S. (1983). Augmentation cystoplasty in the treatment of neurogenic bladder dysfunction. J Urol.
1305 Lindholm P, Lose G. (1986). Terbutaline (Bricanyl) in the treatment of female urge incontinence. Urol Int.
1306 Lindseth PD, Lindseth GN. (1992). Assessing for preflight predictors of airsickness. Aviat Space Environ Med.
1307 Linn JF, Hohenfellner M, Roth S, et al. (1998). Treatment of interstitial cystitis: comparison of subtrigonal and supratrigonal cystectomy combined with orthotopic bladder substitution. J Urol.
1308 Lipton RB, Kolodner K, Wesnes K. (2005). Assessment of cognitive function of the elderly population: effects of darifenacin. J Urol.
1309 Litwiller SE, Nelson RS, Fone PD, et al. (1997). Vaginal wall sling: long-term outcome analysis of factors contributing to patients satisfaction and surgical success. J Urol.
1310 Liu CY. (1993). Laparoscopic retropubic colposuspension (Burch procedure). A review of 58 cases. J Reprod Med.
1311 Liu HT, Chancellor MB, Kuo HC. (2008). Urinary nerve growth factor level could be a biomarker in the differential diagnosis of mixed urinary incontinence in women. BJU Int.
1312 Liu HT, Kuo HC. (2007). Increased expression of transient receptor potential vanilloid subfamily 1 in the bladder predicts the response to intravesical instillations of resiniferatoxin in patients with refractory idiopathic detrusor overactivity. BJU Int.
1313 Liu HT, Kuo HC. (2008). Urinary nerve growth factor level could be a potential biomarker for diagnosis of overactive bladder. J Urol.
1314 Liu HT, Kuo HC. (2009). Urinary nerve growth factor levels are elevated in patients with overactive bladder and do not significantly increase with bladder distention. Neurourol Urodyn.
1315 Liu L, Mansfield KJ, Kristiana I, et al. (2007). The molecular basis of urgency: regional difference of vanilloid receptor expression in the human urinary bladder. Neurourol Urodyn.
1316 Lloyd SN, Lloyd SM, Rogers K, et al. (1992). Is there still a place for prolonged bladder distension?. Br J Urol.
1317 Lo SK, Naidu J, Cao Y. (2003). Additive effect of interferential therapy over pelvic floor exercise alone in the treatment of female urinary stress and urge incontinence: a randomized controlled trial. Hong Kong Physiotherapy Journal.
1318 Lo TS, Chang TC, Chao AS, et al. (2003). Tension-free vaginal tape procedure on genuine stress incontinent women with coexisting genital prolapse. Acta Obstet Gynecol Scand.
1319 Lo TS, Horng SG, Chang CL, et al. (2002). Tension-free vaginal tape procedure after previous failure in incontinence surgery. Urology.
1320 Lo TS, Huang HJ, Chang CL, et al. (2002). Use of intravenous anesthesia for tension-free vaginal tape therapy in elderly women with genuine stress incontinence. Urology.
1321 Lo TS, Lin CT, Huang HJ, et al. (2003). The use of general anesthesia for the tension-free vaginal tape procedure and concomitant surgery. Acta Obstet Gynecol Scand.
1322 Locher JL, Goode PS, Roth DL, et al. (2001). Reliability assessment of the bladder diary for urinary incontinence in older women. J Gerontol A Biol Sci Med Sci.
1323 Lockhart JL, Ellis GF, Helal M, et al. (1990). Combined cystourethropexy for the treatment of type 3 and complicated female urinary incontinence. J Urol.
1324 Lockhart JL, Shessel F, Weinstein D, et al. (1982). Urodynamics in women with stress and urge incontinence. Urology.
1325 Loddenkemper T, Foldvary N, Raja S, et al. (2003). Ictal urinary urge: further evidence for lateralization to the nondominant hemisphere. Epilepsia.
1326 Long CY, Hsu SC, Chen YH, et al. (2001). The effects on vesicourethral function following laparoscopic hysterectomy. Kaohsiung J Med Sci.
1327 Long CY, Hsu SC, Sun DJ, et al. (2002). Abnormal clinical and urodynamic findings in women with severe genitourinary prolapse. Kaohsiung J Med Sci.
1328 Long CY, Hsu SC, Wu TP, et al. (2003). Effect of laparoscopic hysterectomy on bladder neck and urinary symptoms. Aust N Z J Obstet Gynaecol.
1329 Long CY, Hsu SC, Wu TP, et al. (2004). Urodynamic comparison of continent and incontinent women with severe uterovaginal prolapse. J Reprod Med.
1330 Long CY, Jang MY, Chen SC, et al. (2002). Changes in vesicourethral function following laparoscopic hysterectomy versus abdominal hysterectomy. Aust N Z J Obstet Gynaecol.
1331 Long CY, Liu CM, Hsu SC, et al. (2006). A randomized comparative study of the effects of oral and topical estrogen therapy on the lower urinary tract of hysterectomized postmenopausal women. Fertil Steril.
1332 Loomis ME, Conco D. (1991). Patients’ perceptions of health, chronic illness, and nursing diagnoses. Nurs Diagn.
1333 Lopez Pereira P, Miguelez C, Caffarati J, et al. (2003). Trospium chloride for the treatment of detrusor instability in children. J Urol.
1334 Lorenzo AJ, Wallis MC, Cook A, et al. (2007). What is the variability in urodynamic parameters with position change in children? Analysis of a prospectively enrolled cohort. J Urol.
1335 Lose G, Jorgensen L, Thunedborg P. (1989). Doxepin in the treatment of female detrusor overactivity: a randomized double-blind crossover study. J Urol.
1336 Lowenstein L, FitzGerald MP, Kenton K, et al. (2008). Validation of a real-time urodynamic measure of urinary sensation. Am J Obstet Gynecol.
1337 Lowenstein L, Kenton K, Brubaker L, et al. (2008). The relationship between obstructive sleep apnea, nocturia, and daytime overactive bladder syndrome in women. Am J Obstet Gynecol.
1338 Lowenstein L, Kenton K, Dooley Y, et al. (2008). Women who experience detrusor overactive at lower bladder volumes report greater bother. Neurourol Urodyn.
1339 Lowenstein L, Kenton K, FitzGerald MP, et al. (2008). Clinically useful measures in women with mixed urinary incontinence. Am J Obstet Gynecol.
1340 Lubeck DP, Prebil LA, Peeples P, et al. (1999). A health related quality of life measure for use in patients with urge urinary incontinence: a validation study. Qual Life Res.
1341 Luber KM, Wolde-Tsadik G. (1997). Efficacy of functional electrical stimulation in treating genuine stress incontinence: a randomized clinical trial. Neurourol Urodyn.
1342 Lucas MG, Thomas DG. (1987). Endoscopic bladder transection for detrusor instability. Br J Urol.
1343 Lucas MG, Thomas DG, Clarke S, et al. (1988). Long-term follow-up of selective sacral neurectomy. Br J Urol.
1344 Lucioni A, Rapp DE, Gong EM, et al. (2006). Intravesical botulinum type A toxin injection in patients with overactive bladder: Trigone versus trigone-sparing injection. Can J Urol.
1345 Lukacz ES, Lawrence JM, Buckwalter JG, et al. (2005). Epidemiology of prolapse and incontinence questionnaire: validation of a new epidemiologic survey. Int Urogynecol J Pelvic Floor Dysfunct.
1346 Lutgendorf SK, Kreder KJ, Rothrock NE, et al. (2002). Diurnal cortisol variations and symptoms in patients with interstitial cystitis. J Urol.
1347 Luukinen H, Koski K, Kivela SL, et al. (1996). Social status, life changes, housing conditions, health, functional abilities and life-style as risk factors for recurrent falls among the home-dwelling elderly. Public Health.
1348 Maake C, Landman M, Wang X, et al. (2006). Expression of smoothelin in the normal and the overactive human bladder. J Urol.
1349 Macaulay AJ, Stern RS, Stanton SL. (1991). Psychological aspects of 211 female patients attending a urodynamic unit. J Psychosom Res.
1350 MacDiarmid SA, Anderson RU, Armstrong RB, et al. (2005). Efficacy and safety of extended release oxybutynin for the treatment of urge incontinence: an analysis of data from 3 flexible dosing studies. J Urol.
1351 Macfarlane JR, Tolley DA. (1984). The effect of terodiline on patients with detrusor instability. Scand J Urol Nephrol Suppl.
1352 Madeiro AP, Rufino AC, Sartori MG, et al. (2006). The effects of bethanechol and cisapride on urodynamic parameters in patients undergoing radical hysterectomy for cervical cancer. A randomized, double-blind, placebo-controlled study. Int Urogynecol J Pelvic Floor Dysfunct.
1353 Madersbacher H, Halaska M, Voigt R, et al. (1999). A placebo-controlled, multicentre study comparing the tolerability and efficacy of propiverine and oxybutynin in patients with urgency and urge incontinence. BJU Int.
1354 Madersbacher S, Pycha A, Klingler CH, et al. (1999). The International Prostate Symptom score in both sexes: a urodynamics-based comparison. Neurourol Urodyn.
1355 Madersbacher S, Pycha A, Schatzl G, et al. (1998). The aging lower urinary tract: a comparative urodynamic study of men and women. Urology.
1356 Madjar S, Covington-Nichols C, Secrest CL. (2003). New periurethral bulking agent for stress urinary incontinence: modified technique and early results. J Urol.
1357 Mahady IW, Begg BM. (1981). Long-term symptomatic and cystometric cure of the urge incontinence syndrome using a technique of bladder re-education. Br J Obstet Gynaecol.
1358 Mahajan ST, Elkadry EA, Kenton KS, et al. (2006). Patient-centered surgical outcomes: the impact of goal achievement and urge incontinence on patient satisfaction one year after surgery. Am J Obstet Gynecol.
1359 Mahawong P, Chaiyaprasithi B, Soontrapa S, et al. (2007). A role of intravesical capsaicin instillation in benign prostatic hyperplasia with overactive bladder symptoms: the first reported study in the literature. J Med Assoc Thai.
1360 Maher C, Carey M, Dwyer P, et al. (2001). Pubovaginal or vicryl mesh rectus fascia sling in intrinsic sphincter deficiency. Int Urogynecol J Pelvic Floor Dysfunct.
1361 Maher C, Dwyer P, Carey M, et al. (1999). The Burch colposuspension for recurrent urinary stress incontinence following retropubic continence surgery. Br J Obstet Gynaecol.
1362 Maher CF, Dwyer PL, Carey MP, et al. (1999). Colposuspension or sling for low urethral pressure stress incontinence?. Int Urogynecol J Pelvic Floor Dysfunct.
1363 Mahony DT, Laferte RO, Blais DJ. (1980). Incontinence of urine due to instability of micturition reflexes. Part II. Pudendal nucleus instability. Urology.
1364 Mahony DT, Laferte RO, Blais DJ. (1980). Incontinence of urine due to instability of micturition reflexes: Part I. Detrusor reflex instability. Urology.
1365 Major H, Culligan P, Heit M. (2002). Urethral sphincter morphology in women with detrusor instability. Obstet Gynecol.
1366 Makinen JI, Pitkanen YA, Salmi TA, et al. (1995). Transdermal estrogen for female stress urinary incontinence in postmenopause. Maturitas.
1367 Malm-Buatsi E, Nepple KG, Boyt MA, et al. (2007). Efficacy of transcutaneous electrical nerve stimulation in children with overactive bladder refractory to pharmacotherapy. Urology.
1368 Malone RP, Delaney MA, Luebbert JF, et al. (2000). A double-blind placebo-controlled study of lithium in hospitalized aggressive children and adolescents with conduct disorder. Arch Gen Psychiatry.
1369 Malone-Lee J, Shaffu B, Anand C, et al. (2001). Tolterodine: superior tolerability than and comparable efficacy to oxybutynin in individuals 50 years old or older with overactive bladder: a randomized controlled trial. J Urol.
1370 Malone-Lee JG, Walsh JB, Maugourd MF. (2001). Tolterodine: a safe and effective treatment for older patients with overactive bladder. J Am Geriatr Soc.
1371 Malouf AJ, Vaizey CJ, Nicholls RJ, et al. (2000). Permanent sacral nerve stimulation for fecal incontinence. Ann Surg.
1372 Manca A, Sculpher MJ, Ward K, et al. (2003). A cost-utility analysis of tension-free vaginal tape versus colposuspension for primary urodynamic stress incontinence. BJOG.
1373 Manning J, Eyers AA, Korda A, et al. (2001). Is there an association between fecal incontinence and lower urinary dysfunction?. Dis Colon Rectum.
1374 Manonai J, Chittacharoen A, Sarit-apirak S, et al. (2004). Lower urinary tract symptoms in Thai women attending the menopause clinic: prevalence and associated factors. J Med Assoc Thai.
1375 Manonai J, Songchitsomboon S, Chanda K, et al. (2006). The effect of a soy-rich diet on urogenital atrophy: a randomized, cross-over trial. Maturitas.
1376 Mansfield KJ, Liu L, Moore KH, et al. (2007). Molecular characterization of M2 and M3 muscarinic receptor expression in bladder from women with refractory idiopathic detrusor overactivity. BJU Int.
1377 Marinkovic SP, Stanton SL. (2003). Triple compartment prolapse: sacrocolpopexy with anterior and posterior mesh extensions. BJOG.
1378 Mark SD, McRae CU, Arnold EP, et al. (1994). Clam cystoplasty for the overactive bladder: a review of 23 cases. Aust N Z J Surg.
1379 Martin MR, James ED. (1981). Treatment of unstable detrusor (irritable bladder) using fluphenazine and nortriptyline: progress report. Prog Clin Biol Res.
1380 Martin MR, Schiff AA. (1984). Fluphenazine/nortriptyline in the irritable bladder syndrome. A double-blind placebo controlled study. Br J Urol.
1381 Martinez JM, Russell JM, Hirschfeld RM. (1998). Tolerability of oral loading of divalproex sodium in the treatment of acute mania. Depress Anxiety.
1382 Mascarenhas F, Cocuzza M, Gomes CM, et al. (2008). Trigonal injection of botulinum toxin-A does not cause vesicoureteral reflux in neurogenic patients. Neurourol Urodyn.
1383 Mason RC, Roach M. (1996). Modified pubovaginal sling for treatment of intrinsic sphincteric deficiency. J Urol.
1384 Massey JA, Abrams P. (1986). Dose titration in clinical trials. An example using emepronium carrageenate in detrusor instability. Br J Urol.
1385 Mastropietro MA, Geary W, Fuller E, et al. (2001). Detrusor biopsy as a potential clinical tool. Int Urogynecol J Pelvic Floor Dysfunct.
1386 Masunaga K, Yoshida M, Inadome A, et al. (2008). Pharmacological effects of solifenacin on human isolated urinary bladder. Pharmacology.
1387 Matharu G, Donaldson MM, McGrother CW, et al. (2005). Relationship between urinary symptoms reported in a postal questionnaire and urodynamic diagnosis. Neurourol Urodyn.
1388 Matharu GS, Assassa RP, Williams KS, et al. (2004). Objective assessment of urinary incontinence in women: comparison of the one-hour and 24-hour pad tests. Eur Urol.
1389 Matharu GS, Assassa RP, Williams KS, et al. (2004). Continence nurse treatment of women’s urinary symptoms. Br J Nurs.
1390 Mattiasson A, Ekstrom B, Andersson KE. (1989). Effects of intravesical instillation of verapamil in patients with detrusor hyperactivity. J Urol.
1391 Mattiasson A, Teleman P. (2006). Abnormal urethral motor function is common in female stress, mixed, and urge incontinence. Neurourol Urodyn.
1392 Mattox TF, Bhatia NN. (1996). The prevalence of urinary incontinence or prolapse among white and Hispanic women. Am J Obstet Gynecol.
1393 Mattsson S, Gladh G. (2003). Urethrovaginal reflux--a common cause of daytime incontinence in girls. Pediatrics.
1394 Matza LS, Thompson CL, Krasnow J, et al. (2005). Test-retest reliability of four questionnaires for patients with overactive bladder: the overactive bladder questionnaire (OAB-q), patient perception of bladder condition (PPBC), urgency questionnaire (UQ), and the primary OAB symptom questionnaire (POSQ). Neurourol Urodyn.
1395 Mayo ME. (1981). Pelvic floor function in women with detrusor instability. Prog Clin Biol Res.
1396 Mazur D, Wehnert J, Dorschner W, et al. (1995). Clinical and urodynamic effects of propiverine in patients suffering from urgency and urge incontinence. A multicentre dose-optimizing study. Scand J Urol Nephrol.
1397 McAchran SE, Daneshgari F. (2007). Sacral neuromodulation in the older woman. Clin Obstet Gynecol.
1398 McCahy PJ, Styles RA. (1995). Prolonged bladder distension: experience in the treatment of detrusor overactivity and interstitial cystitis. Eur Urol.
1399 McCannel DA, Haile W. (1982). Urethral narrowing and its treatment: a possible solution for the problems of recurrent urinary infection and the “irritable bladder”. Int Urol Nephrol.
1400 McClish DK, Fantl JA, Wyman JF, et al. (1991). Bladder training in older women with urinary incontinence: relationship between outcome and changes in urodynamic observations. Obstet Gynecol.
1401 McClish DK, Wyman JF, Sale PG, et al. (1999). Use and costs of incontinence pads in female study volunteers. Continence Program for Women Research Group. J Wound Ostomy Continence Nurs.
1402 McCrery R, Appell R. (2007). Transvaginal urethrolysis for obstruction after antiincontinence surgery. Int Urogynecol J Pelvic Floor Dysfunct.
1403 McDowell BJ, Burgio KL, Dombrowski M, et al. (1992). An interdisciplinary approach to the assessment and behavioral treatment of urinary incontinence in geriatric outpatients. J Am Geriatr Soc.
1404 McGuire EJ. (1984). Symptoms that depress the doctor. Urge incontinence. Br J Hosp Med.
1405 McInerney PD, Harris SA, Pritchard A, et al. (1991). Night studies for primary diurnal and nocturnal enuresis and preliminary results of the “clam” ileocystoplasty. Br J Urol.
1406 McInerney PD, Vanner TF, Harris SA, et al. (1991). Ambulatory urodynamics. Br J Urol.
1407 McInerney PD, Vanner TF, Matenhelia S, et al. (1991). Assessment of the long-term results of subtrigonal phenolisation. Br J Urol.
1408 McKenna SP, Whalley D, Renck-Hooper U, et al. (1999). The development of a quality of life instrument for use with post-menopausal women with urogenital atrophy in the UK and Sweden. Qual Life Res.
1409 McLennan MT. (2003). The role of electrodiagnostic techniques in the reprogramming of patients with a delayed suboptimal response to sacral nerve stimulation. Int Urogynecol J Pelvic Floor Dysfunct.
1410 McLennan MT, Bent AE. (1998). Fascia lata suburethral sling vs. Burch retropubic urethropexy. A comparison of morbidity. J Reprod Med.
1411 McLennan MT, Melick C, Bent AE. (2001). Urethral instability: clinical and urodynamic characteristics. Neurourol Urodyn.
1412 McPherson K, Herbert A, Judge A, et al. (2005). Self-reported bladder function five years post-hysterectomy. J Obstet Gynaecol.
1413 McQuire WA. (1975). Electrotherapy and exercises for stress incontinence and urinary frequency. Physiotherapy.
1414 McRae P, Murray KH, Nurse DE, et al. (1987). Clam enterocystoplasty in the neuropathic bladder. Br J Urol.
1415 Meade-D’Alisera P, Merriweather T, Wentland M. (2001). Impact of commercial marketing on patient demand. Urol Nurs.
1416 Medel R, Ruarte AC, Castera R, et al. (1998). Primary enuresis: a urodynamic evaluation. Br J Urol.
1417 Medina-Bombardo D, Segui-Diaz M, Roca-Fusalba C, et al. (2003). What is the predictive value of urinary symptoms for diagnosing urinary tract infection in women?. Fam Pract.
1418 Menarini M, Del Popolo G, Di Benedetto P, et al. (2006). Trospium chloride in patients with neurogenic detrusor overactivity: is dose titration of benefit to the patients?. Int J Clin Pharmacol Ther.
1419 Merlini E, Sangiorgio L, Seymandi P. (2004). The lazy bladder syndrome: a possible urodynamic evolution in patients with idiopatic detrusor and pelvic floor overactivity. Pediatr Med Chir.
1420 Meschia M, Pifarotti P, Spennacchio M, et al. (2004). A randomized comparison of tension-free vaginal tape and endopelvic fascia plication in women with genital prolapse and occult stress urinary incontinence. Am J Obstet Gynecol.
1421 Messing E, Pauk D, Schaeffer A, et al. (1997). Associations among cystoscopic findings and symptoms and physical examination findings in women enrolled in the Interstitial Cystitis Data Base (ICDB) Study. Urology.
1422 Metcalfe A, Bick D, Tohill S, et al. (2006). A prospective cohort study of repair and non-repair of second-degree perineal trauma: results and issues for future research. Evidence Based Midwifery.
1423 Metello J, Nogueira B, Torgal M, et al. (2007). Comparison of the efficacy and tolerability of solifenacin succinate with or without previous use of trospium chloride. Int Urogynecol J Pelvic Floor Dysfunct.
1424 Meyhoff HH, Gerstenberg TC, Nordling J. (1983). Placebo--the drug of choice in female motor urge incontinence?. Br J Urol.
1425 Meyhoff HH, Walter S, Gerstenberg T, et al. (1981). Incontinence surgery in females with motor urge incontinence. Prog Clin Biol Res.
1426 Meyhoff HH, Walter S, Gerstenberg TC, et al. (1983). Incontinence surgery in female motor urge incontinence. Acta Obstet Gynecol Scand.
1427 Michel MC, de la Rosette JJ, Piro M, et al. (2004). Does concomitant stress incontinence alter the efficacy of tolterodine in patients with overactive bladder?. J Urol.
1428 Milani R, Merlo E, Scalambrino S, et al. (1986). A double-blind trial of fentonium bromide in the treatment of incontinent unstable bladder. Int J Clin Pharmacol Ther Toxicol.
1429 Milani R, Scalambrino S, Carrera S, et al. (1988). Comparison of flavoxate hydrochloride in daily dosages of 600 versus 1200 mg for the treatment of urgency and urge incontinence. J Int Med Res.
1430 Milani R, Scalambrino S, Carrera S, et al. (1988). Flavoxate hydrochloride for urinary urgency after pelvic radiotherapy: comparison of 600 mg versus 1200 mg daily dosages. J Int Med Res.
1431 Milisen K, Dejaeger E, Braes T, et al. (2006). Process evaluation of a nurse-led multifactorial intervention protocol for risk screening and assessment of fall problems among community-dwelling older persons: a pilot-study. J Nutr Health Aging.
1432 Millard RJ, Halaska M. (2006). Efficacy of solifenacin in patients with severe symptoms of overactive bladder: a pooled analysis. Curr Med Res Opin.
1433 Milleman M, Langenstroer P, Guralnick ML. (2004). Post-void residual urine volume in women with overactive bladder symptoms. J Urol.
1434 Miller EA, Amundsen CL, Toh KL, et al. (2003). Preoperative urodynamic evaluation may predict voiding dysfunction in women undergoing pubovaginal sling. J Urol.
1435 Miller KL, DuBeau CE, Bergmann M, et al. (2002). Quest for a detrusor overactivity index. J Urol.
1436 Mills IW, Greenland JE, McMurray G, et al. (2000). Studies of the pathophysiology of idiopathic detrusor instability: the physiological properties of the detrusor smooth muscle and its pattern of innervation. J Urol.
1437 Minaglia S, Ozel B, Bizhang R, et al. (2005). Increased prevalence of interstitial cystitis in women with detrusor overactivity refractory to anticholinergic therapy. Urology.
1438 Minaglia S, Ozel B, Nguyen JN, et al. (2005). Validation of Spanish version of Pelvic Pain and Urgency/Frequency (PUF) patient symptom scale. Urology.
1439 Minardi D, Piloni V, Amadi A, et al. (2007). Correlation between urodynamics and perineal ultrasound in female patients with urinary incontinence. Neurourol Urodyn.
1440 Minassian VA, Lovatsis D, Pascali D, et al. (2006). Effect of childhood dysfunctional voiding on urinary incontinence in adult women. Obstet Gynecol.
1441 Misawa T, Kamimura M, Kinoshita T, et al. (2005). Neurogenic bladder in patients with cervical compressive myelopathy. J Spinal Disord Tech.
1442 Mishail A, Shahsavari M, Kim J, et al. (2008). Deficits in urological knowledge among medical students and primary care providers: potential for impact on urological care. J Urol.
1443 Mitsui T, Tanaka H, Moriya K, et al. (2008). Outcomes of lower urinary and bowel function in meningomyelocele patients with augmentation enterocystoplasty. Spinal Cord.
1444 Miyamae K, Yoshida M, Murakami S, et al. (2003). Pharmacological effects of darifenacin on human isolated urinary bladder. Pharmacology.
1445 Moen M, Stien R. (1982). Urge incontinence. Ann Chir Gynaecol.
1446 Moisey CU, Stephenson TP, Brendler CB. (1980). The urodynamic and subjective results of treatment of detrusor instability with oxybutynin chloride. Br J Urol.
1447 Moiyadi AV, Devi BI, Nair KP. (2007). Urinary disturbances following traumatic brain injury: clinical and urodynamic evaluation. NeuroRehabilitation.
1448 Molander U, Milsom I, Ekelund P, et al. (1990). An epidemiological study of urinary incontinence and related urogenital symptoms in elderly women. Maturitas.
1449 Mold JW. (1996). Pharmacotherapy of urinary incontinence. Am Fam Physician.
1450 Monga AK, Marrero JM, Stanton SL, et al. (1997). Is there an irritable bladder in the irritable bowel syndrome?. Br J Obstet Gynaecol.
1451 Montz FJ, Stanton SL. (1986). Q-Tip test in female urinary incontinence. Obstet Gynecol.
1452 Monz B, Chartier-Kastler E, Hampel C, et al. (2007). Patient characteristics associated with quality of life in European women seeking treatment for urinary incontinence: results from PURE. Eur Urol.
1453 Moore K, Griffiths D, Latimer G, et al. (1993). Twenty four-hour monitoring of incontinence and bladder function in a community hospital. J ET Nurs.
1454 Moore KH, Foote A, Siva S, et al. (1997). The use of the bladder neck support prosthesis in combined genuine stress incontinence and detrusor instability. Aust N Z J Obstet Gynaecol.
1455 Moore KH, Gilpin SA, Dixon JS, et al. (1992). Increase in presumptive sensory nerves of the urinary bladder in idiopathic detrusor instability. Br J Urol.
1456 Moore KH, Lam DS, Lynch W, et al. (2002). The tachykinin NK-2 receptor antagonist SR48968 does not block noncholinergic contractions in unstable human bladder. Peptides.
1457 Moore KH, O’Sullivan RJ, Simons A, et al. (2003). Randomised controlled trial of nurse continence advisor therapy compared with standard urogynaecology regimen for conservative incontinence treatment: efficacy, costs and two year follow up. BJOG.
1458 Moore KH, Richmond DH, Parys BT. (1991). Sex distribution of adult idiopathic detrusor instability in relation to childhood bedwetting. Br J Urol.
1459 Moore KH, Simons A, Mukerjee C, et al. (2000). The relative incidence of detrusor instability and bacterial cystitis detected on the urodynamic-test day. BJU Int.
1460 Morabito F, Rossi R, Graziano ME, et al. (2006). Multicenter study on the use of gemcitabine to prevent recurrence of multiple-recurring superficial bladder tumors following intravesical antiblastic agents and/or BCG: evaluation of tolerance. Arch Ital Urol Androl.
1461 Moran PA, Dwyer PL, Carey MP, et al. (1999). Oral methotrexate in the management of refractory interstitial cystitis. Aust N Z J Obstet Gynaecol.
1462 Moran PA, Ward KL, Johnson D, et al. (2000). Tension-free vaginal tape for primary genuine stress incontinence: a two-centre follow-up study. BJU Int.
1463 Morgan JE, Heritz DM, Stewart FE, et al. (1995). The polypropylene pubovaginal sling for the treatment of recurrent stress urinary incontinence. J Urol.
1464 Morgan TO, Westney OL, McGuire EJ. (2000). Pubovaginal sling: 4-YEAR outcome analysis and quality of life assessment. J Urol.
1465 Morita T, Iizuka H, Iwata T, et al. (2000). Function and distribution of beta3-adrenoceptors in rat, rabbit and human urinary bladder and external urethral sphincter. J Smooth Muscle Res.
1466 Morkved S, Bo K. (2000). Effect of postpartum pelvic floor muscle training in prevention and treatment of urinary incontinence: a one-year follow up. BJOG.
1467 Morris AR, O’Sullivan R, Dunkley P, et al. (2007). Extracorporeal magnetic stimulation is of limited clinical benefit to women with idiopathic detrusor overactivity: a randomized sham controlled trial. Eur Urol.
1468 Morris AR, Westbrook JI, Moore KH. (2008). A longitudinal study over 5 to 10 years of clinical outcomes in women with idiopathic detrusor overactivity. BJOG.
1469 Morrison LM, Eadie AS, McAlister A, et al. (1986). Personality testing in 226 patients with urinary incontinence. Br J Urol.
1470 Moser F, Bjelic-Radisic V, Tamussino K. (2006). Needle suspension of the bladder neck for stress urinary incontinence: objective results at 11 to 16 years. Int Urogynecol J Pelvic Floor Dysfunct.
1471 Moskowitz MO, Byrne DS, Callahan HJ, et al. (1994). Decreased expression of a glycoprotein component of bladder surface mucin (GP1) in interstitial cystitis. J Urol.
1472 Mosley LJ, Lee GP, Hughes ML, et al. (2003). Analysis of symptoms, functional impairments, and participation in occupational therapy for individuals with multiple sclerosis. Occupational Therapy in Health Care.
1473 Mukerji G, Waters J, Chessell IP, et al. (2006). Pain during ice water test distinguishes clinical bladder hypersensitivity from overactivity disorders. BMC Urol.
1474 Mulholland SG. (1999). UTI in women: how best to treat acute and recurrent infections... urinary tract infection (UTI). Consultant (00107069).
1475 Muller SC, Frohneberg D, Schwab R, et al. (1986). Selective sacral nerve blockade for the treatment of unstable bladders. Eur Urol.
1476 Mulvany NJ, Riley CB. (1997). Granulosa cell tumors of unilocular cystic type. Pathology.
1477 Munding M, Wessells H, Thornberry B, et al. (2001). Use of tolterodine in children with dysfunctional voiding: an initial report. J Urol.
1478 Mundy AR. (1980). Bladder transection for urge incontinence associated with detrusor instability. Br J Urol.
1479 Mundy AR. (1982). The surgical treatment of urge incontinence of urine. J Urol.
1480 Mundy AR, Stephenson TP. (1985). “Clam” ileocystoplasty for the treatment of refractory urge incontinence. Br J Urol.
1481 Murakami S, Yoshida M, Iwashita H, et al. (2003). Pharmacological effects of KRP-197 on the human isolated urinary bladder. Urol Int.
1482 Murphy EL, Glynn SA, Fridey J, et al. (1997). Increased prevalence of infectious diseases and other adverse outcomes in human T lymphotropic virus types I- and II-infected blood donors. Retrovirus Epidemiology Donor Study (REDS) Study Group. J Infect Dis.
1483 Murray C, Goh JT, Fynes M, et al. (2002). Urinary and faecal incontinence following delayed primary repair of obstetric genital fistula. BJOG.
1484 Murray K, Mundy AR, Blackford HN, et al. (1986). Transvesical phenolisation of the pelvic plexuses: a simple technique for the treatment of refractory detrusor instability and hyperreflexia. Urol Int.
1485 Murray KH. (1983). Effect of naloxone-induced opioid blockade on idiopathic detrusor instability. Urology.
1486 Musa AA. (2008). Use of double-J stents prior to extracorporeal shock wave lithotripsy is not beneficial: results of a prospective randomized study. Int Urol Nephrol.
1487 Muskat Y, Bukovsky I, Schneider D, et al. (1996). The use of scopolamine in the treatment of detrusor instability. J Urol.
1488 Musselman DM, Ford AP, Gennevois DJ, et al. (2004). A randomized crossover study to evaluate Ro 115–1240, a selective alpha1A/1L-adrenoceptor partial agonist in women with stress urinary incontinence. BJU Int.
1489 Mustafa M, Wadie BS. (2006). Placard-shaped in situ vaginal wall sling for the treatment of stress urinary incontinence. Int J Urol.
1490 Myren CJ, Beuke HP, Thybo E. (1988). Functional results after ileocystoplasty. Int Urol Nephrol.
1491 Nabi G, Singh I, Ansari MS, et al. (2001). Primary small cell neuroendocrine carcinoma of urinary bladder: an uncommon entity to be recognized. Int Urol Nephrol.
1492 Nager CW, Albo ME, Fitzgerald MP, et al. (2007). Reference urodynamic values for stress incontinent women. Neurourol Urodyn.
1493 Nager CW, FitzGerald M, Kraus SR, et al. (2008). Urodynamic measures do not predict stress continence outcomes after surgery for stress urinary incontinence in selected women. J Urol.
1494 Naglie G, Radomski SB, Brymer C, et al. (2002). A randomized, double-blind, placebo controlled crossover trial of nimodipine in older persons with detrusor instability and urge incontinence. J Urol.
1495 Nakamura M, Sakurai T, Sugao H, et al. (1987). Maximum electrical stimulation for urge incontinence. Urol Int.
1496 Nakamura M, Sakurai T, Tsujimoto Y, et al. (1986). Bladder inhibition by electrical stimulation of the perianal skin. Urol Int.
1497 Nama G. (2007). Toilet tied. Nursing in the Community.
1498 Naoemova I, De Wachter S, Wuyts FL, et al. (2008). Do sensation-related bladder diaries differ between patients with urodynamically confirmed and non-objectivised urinary incontinence?. Int Urogynecol J Pelvic Floor Dysfunct.
1499 Naoemova I, De Wachter S, Wuyts FL, et al. (2008). Reliability of the 24-h sensation-related bladder diary in women with urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
1500 Naoemova I, De Wachter S, Wyndaele JJ. (2008). Comparison of sensation-related voiding patterns between continent and incontinent women: a study with a 3-day sensation-related bladder diary (SR-BD). Neurourol Urodyn.
1501 Natsume O. (2008). Detrusor contractility and overactive bladder in patients with cerebrovascular accident. Int J Urol.
1502 Nauth MA, Funfgeld C. (2008). Correction of cystocele and stress incontinence with anterior transobturator mesh. Eur J Obstet Gynecol Reprod Biol.
1503 Nazarko L. (2005). Management of a patient with diabetes and a hypotonic bladder. Nurs Times.
1504 Nazarko L. (2006). Treating the person with an overactive bladder. Nursing & Residential Care.
1505 Nazarko L. (2007). Stroke and continence: the benefits of assessment. Nursing & Residential Care.
1506 Nazir M, Stien R, Carlsen E, et al. (2003). Early evaluation of bowel symptoms after primary repair of obstetric perineal rupture is misleading: an observational cohort study. Dis Colon Rectum.
1507 Ndamba J, Nyazema N, Makaza N, et al. (1994). Traditional herbal remedies used for the treatment of urinary schistosomiasis in Zimbabwe. J Ethnopharmacol.
1508 N’Dow J, Leung HY, Marshall C, et al. (1998). Bowel dysfunction after bladder reconstruction. J Urol.
1509 Nejat F, Radmanesh F, Ansari S, et al. (2008). Spina bifida occulta: is it a predictor of underlying spinal cord abnormality in patients with lower urinary tract dysfunction?. J Neurosurg Pediatrics.
1510 Nelson MS. (1986). Acute urinary retention secondary to an incarcerated gravid uterus. Am J Emerg Med.
1511 Neuhaus J, Pfeiffer F, Wolburg H, et al. (2005). Alterations in connexin expression in the bladder of patients with urge symptoms. BJU Int.
1512 Neumann G, Olesen PG, Hansen V, et al. (2004). The short-term prevalence of de novo urinary symptoms after different modes of hysterectomy. Int Urogynecol J Pelvic Floor Dysfunct.
1513 Neumann GA, Lauszus FF, Ljungstrom B, et al. (2007). Incidence and remission of urinary incontinence after hysterectomy--a 3-year follow-up study. Int Urogynecol J Pelvic Floor Dysfunct.
1514 Neveus T, Hetta J, Cnattingius S, et al. (1999). Depth of sleep and sleep habits among enuretic and incontinent children. Acta Paediatr.
1515 Newman DK. (2004). Report of a mail survey of women with bladder control disorders. Urol Nurs.
1516 Newton M, Kosier JH, Smith D. (2000). Treatments for overactive bladder. Urol Nurs.
1517 Ney P, Pandita RK, Newgreen DT, et al. (2008). Pharmacological characterization of a novel investigational antimuscarinic drug, fesoterodine, in vitro and in vivo. BJU Int.
1518 Ng CC, Lee LC, Han WH. (2005). Use of three-dimensional ultrasound scan to assess the clinical importance of midurethral placement of the tension-free vaginal tape (TVT) for treatment of incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
1519 Ng S, Tee YT, Tsui KP, et al. (2007). Is the role of Burch colposuspension fading away in this epoch for treating female urinary incontinence?. Int Urogynecol J Pelvic Floor Dysfunct.
1520 Ng SC, Lin TL, Chang SJ, et al. (2008). Nursing intervention to enhance efficacy of home practice of pelvic floor muscle exercises in treating mixed urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
1521 Nguyen A, Mahoney S, Minor L, et al. (1999). A simple objective method of adjusting sling tension. J Urol.
1522 Nguyen JK, Bhatia NN. (2001). Resolution of motor urge incontinence after surgical repair of pelvic organ prolapse. J Urol.
1523 Nguyen JK, Bhatia NN. (2001). Risk of recurrent stress incontinence in women undergoing the combined modified pereyra procedure and transvaginal sacrospinous ligament vault suspension. Urology.
1524 Nickel JC, Tripp D, Teal V, et al. (2007). Sexual function is a determinant of poor quality of life for women with treatment refractory interstitial cystitis. J Urol.
1525 Nicolson P, Kopp Z, Chapple CR, et al. (2008). It’s just the worry about not being able to control it! A qualitative study of living with overactive bladder. Br J Health Psychol.
1526 Nigro DA, Wein AJ, Foy M, et al. (1997). Associations among cystoscopic and urodynamic findings for women enrolled in the Interstitial Cystitis Data Base (ICDB) Study. Urology.
1527 Nijman RJ, Borgstein NG, Ellsworth P, et al. (2005). Tolterodine treatment for children with symptoms of urinary urge incontinence suggestive of detrusor overactivity: results from 2 randomized, placebo controlled trials. J Urol.
1528 Nijman RJ, Borgstein NG, Ellsworth P, et al. (2007). Long-term tolerability of tolterodine extended release in children 5–11 years of age: results from a 12-month, open-label study. Eur Urol.
1529 Nilsson CG, Lukkari E, Haarala M, et al. (1997). Comparison of a 10-mg controlled release oxybutynin tablet with a 5-mg oxybutynin tablet in urge incontinent patients. Neurourol Urodyn.
1530 Nilvebrant L, Andersson KE, Gillberg PG, et al. (1997). Tolterodine--a new bladder-selective antimuscarinic agent. Eur J Pharmacol.
1531 Nissenkorn I, De Jong PR. (2005). A novel surgical technique for implanting a new electrostimulation system for treating female overactive bladder: a preliminary report. BJU Int.
1532 Nissenkorn I, Katz A, Rubinstein R, et al. (1986). Selective effect of nortriptyline on smooth muscle as an anticholinergic drug: a pharmacological and clinical study. Eur Urol.
1533 Nissenkorn I, Shalev M, Radziszewski P, et al. (2004). Patient-adjusted intermittent electrostimulation for treating stress and urge urinary incontinence. BJU Int.
1534 Nitahara KS, Aboseif S, Tanagho EA. (1999). Long-term results of colpocystourethropexy for persistent or recurrent stress urinary incontinence. J Urol.
1535 Nitti VW, Combs AJ. (1996). Correlation of Valsalva leak point pressure with subjective degree of stress urinary incontinence in women. J Urol.
1536 Nitti VW, Dmochowski R, Appell RA, et al. (2006). Efficacy and tolerability of tolterodine extended-release in continent patients with overactive bladder and nocturia. BJU Int.
1537 Nitti VW, Tu LM, Gitlin J. (1999). Diagnosing bladder outlet obstruction in women. J Urol.
1538 Nixon A, Colman S, Sabounjian L, et al. (2005). A validated patient reported measure of urinary urgency severity in overactive bladder for use in clinical trials. J Urol.
1539 Noblett KL, Jensen JK, Ostergard DR. (1997). The relationship of body mass index to intra-abdominal pressure as measured by multichannel cystometry. Int Urogynecol J Pelvic Floor Dysfunct.
1540 Nordling J, van Ophoven A. (2008). Intravesical glycosaminoglycan replenishment with chondroitin sulphate in chronic forms of cystitis. A multi-national, multi-centre, prospective observational clinical trial. Arzneimittelforschung.
1541 Norris RD, Sur RL, Springhart WP, et al. (2008). A prospective, randomized, double-blinded placebo-controlled comparison of extended release oxybutynin versus phenazopyridine for the management of postoperative ureteral stent discomfort. Urology.
1542 Norton C, Kamm MA. (1999). Outcome of biofeedback for faecal incontinence. Br J Surg.
1543 Norton P, Karram M, Wall LL, et al. (1994). Randomized double-blind trial of terodiline in the treatment of urge incontinence in women. Obstet Gynecol.
1544 Nuhoglu B, Fidan V, Ayyildiz A, et al. (2006). Stoller afferent nerve stimulation in woman with therapy resistant over active bladder; a 1-year follow up. Int Urogynecol J Pelvic Floor Dysfunct.
1545 Nuotio M, Jylha M, Luukkaala T, et al. (2002). Urgency, urge incontinence and voiding symptoms in men and women aged 70 years and over. BJU Int.
1546 Nuotio M, Tammela TL, Luukkaala T, et al. (2003). Predictors of institutionalization in an older population during a 13-year period: the effect of urge incontinence. J Gerontol A Biol Sci Med Sci.
1547 Nygaard I, Kreder K, Mueller E, et al. (2007). Does urethral competence affect urodynamic voiding parameters in women with prolapse?. Neurourol Urodyn.
1548 Nygaard I, Linder M. (1997). Thirst at work--an occupational hazard?. Int Urogynecol J Pelvic Floor Dysfunct.
1549 Nygaard IE. (1997). Does prolonged high-impact activity contribute to later urinary incontinence? A retrospective cohort study of female Olympians. Obstet Gynecol.
1550 Nygaard IE, Kreder KJ, Lepic MM, et al. (1996). Efficacy of pelvic floor muscle exercises in women with stress, urge, and mixed urinary incontinence. Am J Obstet Gynecol.
1551 Obrink A, Bunne G. (1978). Treatment of urgency by instillation of emepronium bromide in the urinary bladder. Scand J Urol Nephrol.
1552 Obrink A, Bunne G. (1978). Urethrocystometric findings in urgency. Urol Int.
1553 Odegard PS, Setter SM. (2006). Geriatric pharmacotherapy update: new medications, recent releases, and coming attractions. Annals of Long Term Care.
1554 Oga M, Shono H, Kohara M, et al. (1995). Chronological changes in subjective symptoms during pregnancy in nulliparous and multiparous women. Acta Obstet Gynecol Scand.
1555 Ogundipe A, Rosenzweig BA, Karram MM, et al. (1992). Modified suburethral sling procedure for treatment of recurrent or severe stress urinary incontinence. Surg Gynecol Obstet.
1556 Oh SJ, Choo MS, Kim HS, et al. (2008). Generic and disease-specific health-related quality of life in women with coital incontinence: a prospective, multicenter study. Gynecol Obstet Invest.
1557 Oh SJ, Ku JH. (2007). Impact of self-perceived bothersomeness on health-related quality of life in women with overactive bladder symptoms. Urol Int.
1558 Oh SJ, Ku JH. (2007). Impact of stress urinary incontinence and overactive bladder on micturition patterns and health-related quality of life. Int Urogynecol J Pelvic Floor Dysfunct.
1559 Oh SJ, Ku JH, Choo MS, et al. (2008). Health-related quality of life and sexual function in women with stress urinary incontinence and overactive bladder. Int J Urol.
1560 Oh SJ, Ku JH, Hong SK, et al. (2005). Factors influencing self-perceived disease severity in women with stress urinary incontinence combined with or without urge incontinence. Neurourol Urodyn.
1561 Oh SJ, Son H, Jeong JY, et al. (2006). Patients’ experience with ambulatory urodynamics. A prospective study. Scand J Urol Nephrol.
1562 Oh SJ, Son H, Jeong JY, et al. (2007). Anticholinergics [corrected] in patients with overactive bladder: Assessment of ambulatory urodynamics and patient perception. Neurourol Urodyn.
1563 Oh SJ, Son H, Jeong JY, et al. (2007). Antocholinergics in patients with overactive bladder: Assessment of ambulatory urodynamics and patient perception. Neurourol Urodyn.
1564 Ohlsson BL, Fall M, Frankenberg-Sommar S. (1989). Effects of external and direct pudendal nerve maximal electrical stimulation in the treatment of the uninhibited overactive bladder. Br J Urol.
1565 Okada H, Sengoku J, Gohji K, et al. (1998). Clinical effect of propiverine in patients with urge or stress incontinence. Kobe University Incontinence Study Group. Hinyokika Kiyo.
1566 Okada N, Igawa Y, Ogawa A, et al. (1998). Transcutaneous electrical stimulation of thigh muscles in the treatment of detrusor overactivity. Br J Urol.
1567 Okamura K, Hasegawa T, Nojiri Y, et al. (2008). Diagnosis and treatment of lower urinary tract symptoms in the elderly by general practitioners. Geriatr Gerontol Int.
1568 Okamura K, Nojiri Y, Hirano M, et al. (2007). Lower urinary tract symptoms (LUTS) in people aged 50 or older consulting general practitioners. Geriatrics & Gerontology International.
1569 Okorocha I, Cumming G, Gould I. (2002). Female urodynamics and lower urinary tract infection. BJU Int.
1570 Oldenburg B, Millard RJ. (1986). Predictors of long term outcome following a bladder re-training programme. J Psychosom Res.
1571 O’Leary M, Erickson JR, Smith CP, et al. (2003). Effect of controlled-release oxybutynin on neurogenic bladder function in spinal cord injury. J Spinal Cord Med.
1572 Olesen KP, Walter S. (1980). Posterior bladder suspension defects in the female. A radiological classification with urodynamic and clinical evaluation. Acta Obstet Gynecol Scand.
1573 Olesen KP, Walter S, Frimodt-Moller C, et al. (1975). Morphology and function of the bladder and urethra in female urinary incontinence. Int Urol Nephrol.
1574 Oliver S, Fowler C, Mundy A, et al. (2003). Measuring the sensations of urge and bladder filling during cystometry in urge incontinence and the effects of neuromodulation. Neurourol Urodyn.
1575 Olsson B, Landgren BM. (2001). The effect of tolterodine on the pharmacokinetics and pharmacodynamics of a combination oral contraceptive containing ethinyl estradiol and levonorgestrel. Clin Ther.
1576 Olsson B, Szamosi J. (2001). Food does not influence the pharmacokinetics of a new extended release formulation of tolterodine for once daily treatment of patients with overactive bladder. Clin Pharmacokinet.
1577 Olsson B, Szamosi J. (2001). Multiple dose pharmacokinetics of a new once daily extended release tolterodine formulation versus immediate release tolterodine. Clin Pharmacokinet.
1578 Ommer A, Albrecht K, Wenger F, et al. (2006). Stapled transanal rectal resection (STARR): a new option in the treatment of obstructive defecation syndrome. Langenbecks Arch Surg.
1579 Opisso E, Borau A, Rodriguez A, et al. (2008). Patient controlled versus automatic stimulation of pudendal nerve afferents to treat neurogenic detrusor overactivity. J Urol.
1580 Opsomer RJ, Klarskov P, Holm-Bentzen M, et al. (1984). Long term results of superselective sacral nerve resection for motor urge incontinence. Scand J Urol Nephrol.
1581 O’Reilly BA, Kosaka AH, Knight GF, et al. (2002). P2X receptors and their role in female idiopathic detrusor instability. J Urol.
1582 Ornan D, White R, Pollak J, et al. (2003). Pelvic embolization for intractable postpartum hemorrhage: long-term follow-up and implications for fertility. Obstet Gynecol.
1583 Oskay UY, Beji NK, Yalcin O. (2005). A study on urogenital complaints of postmenopausal women aged 50 and over. Acta Obstet Gynecol Scand.
1584 Osman T. (2003). Stress incontinence surgery for patients presenting with mixed incontinence and a normal cystometrogram. BJU Int.
1585 Osorio AV, Alon US. (1997). The relationship between urinary calcium, sodium, and potassium excretion and the role of potassium in treating idiopathic hypercalciuria. Pediatrics.
1586 O’Sullivan R, Karantanis E, Stevermuer TL, et al. (2004). Definition of mild, moderate and severe incontinence on the 24-hour pad test. BJOG.
1587 Ouslander J, Staskin D, Raz S, et al. (1987). Clinical versus urodynamic diagnosis in an incontinent geriatric female population. J Urol.
1588 Ouslander JG. (2002). Geriatric considerations in the diagnosis and management of overactive bladder. Urology.
1589 Ouslander JG, Blaustein J, Connor A, et al. (1988). Pharmacokinetics and clinical effects of oxybutynin in geriatric patients. J Urol.
1590 Ouslander JG, Schnelle JF, Uman G, et al. (1995). Does oxybutynin add to the effectiveness of prompted voiding for urinary incontinence among nursing home residents? A placebo-controlled trial. J Am Geriatr Soc.
1591 Ozel SK, Dokumcu Z, Akyildiz C, et al. (2007). Factors affecting renal scar development in children with spina bifida. Urol Int.
1592 Ozkan KU, Bauer SB, Khoshbin S, et al. (2006). Neurogenic bladder dysfunction after sacrococcygeal teratoma resection. J Urol.
1593 Ozono S, Okajima E, Hirao Y, et al. (1988). Transcatheter arterial embolization of vesical artery in the treatment of invasive bladder cancer. Eur Urol.
1594 Pace G, Aceto G, Cormio L, et al. (1999). Nocturnal enuresis can be caused by absorptive hypercalciuria. Scand J Urol Nephrol.
1595 Pages IH, Jahr S, Schaufele MK, et al. (2001). Comparative analysis of biofeedback and physical therapy for treatment of urinary stress incontinence in women. Am J Phys Med Rehabil.
1596 Paick JS, Kim SW, Ku JH, et al. (2004). Preoperative maximal flow rate may be a predictive factor for the outcome of tension-free vaginal tape procedure for stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
1597 Paick JS, Ku JH, Kim SW, et al. (2004). Tension-free vaginal tape procedure for the treatment of mixed urinary incontinence: significance of maximal urethral closure pressure. J Urol.
1598 Paick JS, Ku JH, Shin JW, et al. (2005). Significance of pad test loss for the evaluation of women with urinary incontinence. Neurourol Urodyn.
1599 Palleschi G, Pastore AL, Stocchi F, et al. (2006). Correlation between the Overactive Bladder questionnaire (OAB-q) and urodynamic data of Parkinson disease patients affected by neurogenic detrusor overactivity during antimuscarinic treatment. Clin Neuropharmacol.
1600 Palma P, Riccetto C, Herrmann V, et al. (2007). Transobturator crossover readjustable sling for severe female incontinence: technique and preliminary results. Int Urogynecol J Pelvic Floor Dysfunct.
1601 Palma PC, Thiel M, Riccetto CL, et al. (2004). Resiniferatoxin for detrusor instability refractory to anticholinergics. Int Braz J Urol.
1602 Palmer J. (1983). Report of a double-blind crossover study of flurbiprofen and placebo in detrusor instability. J Int Med Res.
1603 Panayi DC, Duckett J, Digesu GA, et al. (2009). Pre-operative opening detrusor pressure is predictive of detrusor overactivity following TVT in patients with pre-operative mixed urinary incontinence. Neurourol Urodyn.
1604 Pannek J, Pieper P. (2008). Clinical usefulness of ambulatory urodynamics in the diagnosis and treatment of lower urinary tract dysfunction. Scand J Urol Nephrol.
1605 Papa Petros PE. (1999). Detrusor instability and low compliance may represent different levels of disturbance in peripheral feedback control of the micturition reflex. Neurourol Urodyn.
1606 Papa Petros PE, Ulmsten U. (1999). An anatomical classification--a new paradigm for management of urinary dysfunction in the female. Int Urogynecol J Pelvic Floor Dysfunct.
1607 Parazzini F, Lavezzari M, Arbitani W. (2002). Prevalence of overactive bladder and urinary incontinence. J Fam Pract.
1608 Parekh DJ, Pope JCt, Adams MC, et al. (2001). The use of radiography, urodynamic studies and cystoscopy in the evaluation of voiding dysfunction. J Urol.
1609 Parekh DJ, Pope JI, Adams MC, et al. (2000). The role of hypercalciuria in a subgroup of dysfunctional voiding syndromes of childhood. J Urol.
1610 Parkin DE, Davis JA, Symonds RP. (1987). Long-term bladder symptomatology following radiotherapy for cervical carcinoma. Radiother Oncol.
1611 Parkin DE, Davis JA, Symonds RP. (1988). Urodynamic findings following radiotherapy for cervical carcinoma. Br J Urol.
1612 Parsons CL, Dell J, Stanford EJ, et al. (2002). Increased prevalence of interstitial cystitis: previously unrecognized urologic and gynecologic cases identified using a new symptom questionnaire and intravesical potassium sensitivity. Urology.
1613 Parsons CL, Greenberger M, Gabal L, et al. (1998). The role of urinary potassium in the pathogenesis and diagnosis of interstitial cystitis. J Urol.
1614 Parsons CL, Koprowski PF. (1991). Interstitial cystitis: successful management by increasing urinary voiding intervals. Urology.
1615 Parsons M, Amundsen CL, Cardozo L, et al. (2007). Bladder diary patterns in detrusor overactivity and urodynamic stress incontinence. Neurourol Urodyn.
1616 Parys BT, Woolfenden KA, Parsons KF. (1990). Bladder dysfunction after simple hysterectomy: urodynamic and neurological evaluation. Eur Urol.
1617 Patel AS, O’Leary ML, Stein RJ, et al. (2006). The relationship between overactive bladder and sexual activity in women. Int Braz J Urol.
1618 Paterson J. (2004). Outcomes achieved by an elderly community dwelling population who undertook conservative continence management programs. Geriaction.
1619 Patki P, Hamid R, Somayaji S, et al. (2006). Long-term urological outcomes in paediatric spinal cord injury. Spinal Cord.
1620 Patki PS, Hamid R, Arumugam K, et al. (2006). Botulinum toxin-type A in the treatment of drug-resistant neurogenic detrusor overactivity secondary to traumatic spinal cord injury. BJU Int.
1621 Pauls RN, Marinkovic SP, Silva WA, et al. (2007). Effects of sacral neuromodulation on female sexual function. Int Urogynecol J Pelvic Floor Dysfunct.
1622 Payne C, Allee T. (2009). Goal achievement provides new insights into interstitial cystitis/painful bladder syndrome symptoms and outcomes. Neurourol Urodyn.
1623 Payne CK, Joyce GF, Wise M, et al. (2007). Interstitial cystitis and painful bladder syndrome. J Urol.
1624 Payne CK, Mosbaugh PG, Forrest JB, et al. (2005). Intravesical resiniferatoxin for the treatment of interstitial cystitis: a randomized, double-blind, placebo controlled trial. J Urol.
1625 Peacock LM, Wiskind AK, Wall LL. (1994). Clinical features of urinary incontinence and urogenital prolapse in a black inner-city population. Am J Obstet Gynecol.
1626 Peattie AB, Plevnik S, Stanton SL. (1988). The use of bladder neck electric conductance (BNEC) in the investigation and management of sensory urge incontinence in the female. J R Soc Med.
1627 Peattie AB, Stanton SL. (1989). The Stamey operation for correction of genuine stress incontinence in the elderly woman. Br J Obstet Gynaecol.
1628 Peeker R, Aldenborg F, Fall M. (1997). Nephrogenic adenoma--a study with special reference to clinical presentation. Br J Urol.
1629 Peeker R, Aldenborg F, Fall M. (2000). Complete transurethral resection of ulcers in classic interstitial cystitis. Int Urogynecol J Pelvic Floor Dysfunct.
1630 Peeker R, Haghsheno MA, Holmang S, et al. (2000). Intravesical bacillus Calmette-Guerin and dimethyl sulfoxide for treatment of classic and nonulcer interstitial cystitis: a prospective, randomized double-blind study. J Urol.
1631 Pelosi MA, Pelosi MA. (1997). Stress urinary incontinence. Laparoscopically assisted transvaginal needle suspension. J Reprod Med.
1632 Pelosi MA, Pelosi MA. (1999). Pubic bone suburethral stabilization sling: laparoscopic assessment of a transvaginal operation for the treatment of stress urinary incontinence. J Laparoendosc Adv Surg Tech A.
1633 Pelsang RE, Bonney WW. (1996). Voiding cystourethrography in female stress incontinence. AJR Am J Roentgenol.
1634 Pengelly AW, Booth CM. (1980). A prospective trial of bladder training as treatment for detrusor instability. Br J Urol.
1635 Pengelly AW, Stephenson TP, Milroy EJ, et al. (1978). Results of prolonged bladder distension as treatment for detrusor instability. Br J Urol.
1636 Peretto I, Forlani R, Fossati C, et al. (2007). Discovery of diaryl imidazolidin-2-one derivatives, a novel class of muscarinic M3 selective antagonists (Part 1). J Med Chem.
1637 Perez-Medrano A, Brune ME, Buckner SA, et al. (2007). Structure-activity studies of novel cyanoguanidine ATP-sensitive potassium channel openers for the treatment of overactive bladder. J Med Chem.
1638 Persson J, Bergqvist CE, Wolner-Hanssen P. (2001). An ultra-short perineal pad-test for evaluation of female stress urinary incontinence treatment. Neurourol Urodyn.
1639 Persson-Junemann C, Seemann O, Kohrmann KU, et al. (1993). Comparison of urodynamic findings and response to oxybutynin in nocturnal enuresis. Eur Urol.
1640 Pesce F, Castellano V, Finazzi Agro E, et al. (1997). Voiding dysfunction in patients with spinal cord lesions at the thoracolumbar vertebral junction. Spinal Cord.
1641 Peschers UM, Jundt K, Dimpfl T. (2000). Differences between cough and Valsalva leak-point pressure in stress incontinent women. Neurourol Urodyn.
1642 Peters D. (1984). Terodiline in the treatment of urinary frequency and motor urge incontinence. A controlled multicentre trial. Scand J Urol Nephrol Suppl.
1643 Peters KM, Carey JM, Konstandt DB. (2003). Sacral neuromodulation for the treatment of refractory interstitial cystitis: outcomes based on technique. Int Urogynecol J Pelvic Floor Dysfunct.
1644 Peters KM, Diokno AC, Steinert BW, et al. (1998). The efficacy of intravesical bacillus Calmette-Guerin in the treatment of interstitial cystitis: long-term followup. J Urol.
1645 Peters KM, Konstandt D. (2004). Sacral neuromodulation decreases narcotic requirements in refractory interstitial cystitis. BJU Int.
1646 Petersen T, Chandiramani V, Fowler CJ. (1997). The ice-water test in detrusor hyper-reflexia and bladder instability. Br J Urol.
1647 Petersen T, Pedersen E. (1984). Neurourodynamic evaluation of voiding dysfunction in multiple sclerosis. Acta Neurol Scand.
1648 Petros PE, Ulmsten U. (1993). Bladder instability in women: a premature activation of the micturition reflex. Neurourol Urodyn.
1649 Petros PE, Ulmsten UI. (1990). The combined intravaginal sling and tuck operation. An ambulatory procedure for cure of stress and urge incontinence. Acta Obstet Gynecol Scand Suppl.
1650 Petros PE, Ulmsten UI. (1990). Cure of urge incontinence by the combined intravaginal sling and tuck operation. Acta Obstet Gynecol Scand Suppl.
1651 Petros PE, Ulmsten UI. (1990). Non stress non urge female urinary incontinence--diagnosis and cure: a preliminary report. Acta Obstet Gynecol Scand Suppl.
1652 Petros PP. (1996). The intravaginal slingplasty operation, a minimally invasive technique for cure of urinary incontinence in the female. Aust N Z J Obstet Gynaecol.
1653 Petros PP, Ulmsten U. (1992). Urge incontinence history is an accurate predictor of urge incontinence. Acta Obstet Gynecol Scand.
1654 Petrou SP, Brown JA, Blaivas JG. (1999). Suprameatal transvaginal urethrolysis. J Urol.
1655 Petrou SP, Young PR. (2002). Rate of recurrent stress urinary incontinence after retropubic urethrolysis. J Urol.
1656 Pettersen R, Haig Y, Nakstad PH, et al. (2008). Subtypes of urinary incontinence after stroke: relation to size and location of cerebrovascular damage. Age Ageing.
1657 Pettersen R, Stien R, Wyller TB. (2007). Post-stroke urinary incontinence with impaired awareness of the need to void: clinical and urodynamic features. BJU Int.
1658 Pfister C, Dacher JN, Gaucher S, et al. (1999). The usefulness of a minimal urodynamic evaluation and pelvic floor biofeedback in children with chronic voiding dysfunction. BJU Int.
1659 Pfisterer MH, Griffiths DJ, Rosenberg L, et al. (2006). The impact of detrusor overactivity on bladder function in younger and older women. J Urol.
1660 Pfisterer MH, Griffiths DJ, Rosenberg L, et al. (2007). Parameters of bladder function in pre-, peri-, and postmenopausal continent women without detrusor overactivity. Neurourol Urodyn.
1661 Pfisterer MH, Griffiths DJ, Schaefer W, et al. (2006). The effect of age on lower urinary tract function: a study in women. J Am Geriatr Soc.
1662 Philip J, Willmott S, Irwin P. (2006). Interstitial cystitis versus detrusor overactivity: a comparative, randomized, controlled study of cystometry using saline and 0.3 M potassium chloride. J Urol.
1663 Philip J, Willmott S, Owen D, et al. (2007). A double-blind, randomized controlled trial of cystometry using saline versus 0.3 M potassium chloride infusion in women with overactive bladder syndrome. Neurourol Urodyn.
1664 Philp T, Shah PJ, Worth PH. (1988). Acupuncture in the treatment of bladder instability. Br J Urol.
1665 Piault E, Evans CJ, Espindle D, et al. (2008). Development and validation of the Overactive Bladder Satisfaction (OAB-S) Questionnaire. Neurourol Urodyn.
1666 Pidcock FS, Krishnan C, Crawford TO, et al. (2007). Acute transverse myelitis in childhood: center-based analysis of 47 cases. Neurology.
1667 Pieri S, Agresti P, Morucci M, et al. (2003). Percutaneous treatment of pelvic congestion syndrome. Radiol Med (Torino).
1668 Pikaart DP, Miklos JR, Moore RD. (2006). Laparoscopic removal of pubovaginal polypropylene tension-free tape slings. JSLS.
1669 Pilsgaard K, Mouritsen L. (1999). Follow-up after repair of vaginal vault prolapse with abdominal colposacropexy. Acta Obstet Gynecol Scand.
1670 Pleil AM, Coyne KS, Reese PR, et al. (2005). The validation of patient-rated global assessments of treatment benefit, satisfaction, and willingness to continue--the BSW. Value Health.
1671 Plevnik S, Janez J. (1983). Urethral pressure variations. Urology.
1672 Podesta ML, Castera R, Ruarte AC. (2004). Videourodynamic findings in young infants with severe primary reflux. J Urol.
1673 Podnar S, Trsinar B, Vodusek DB. (2006). Bladder dysfunction in patients with cauda equina lesions. Neurourol Urodyn.
1674 Poggesi A, Pracucci G, Chabriat H, et al. (2008). Urinary complaints in nondisabled elderly people with age-related white matter changes: the Leukoaraiosis And DISability (LADIS) Study. J Am Geriatr Soc.
1675 Ponsky LE, Sharma S, Pandrangi L, et al. (2001). Screening and monitoring for bladder cancer: refining the use of NMP22. J Urol.
1676 Poole CJ, Lightman SL. (1988). Inhibition of vasopressin secretion during migraine. J Neurol Neurosurg Psychiatry.
1677 Poon CI, Zimmern PE. (2006). Is there a role for periurethral collagen injection in the management of urodynamically proven mixed urinary incontinence?. Urology.
1678 Popat R, Apostolidis A, Kalsi V, et al. (2005). A comparison between the response of patients with idiopathic detrusor overactivity and neurogenic detrusor overactivity to the first intradetrusor injection of botulinum-A toxin. J Urol.
1679 Porru D, Usai E. (1994). Standard and extramural ambulatory urodynamic investigation for the diagnosis of detrusor instability-correlated incontinence and micturition disorders. Neurourol Urodyn.
1680 Posey JA, Saif MW, Carlisle R, et al. (2005). Phase 1 study of weekly polyethylene glycol-camptothecin in patients with advanced solid tumors and lymphomas. Clin Cancer Res.
1681 Potts JM, Ward AM, Rackley RR. (2000). Association of chronic urinary symptoms in women and Ureaplasma urealyticum. Urology.
1682 Pow-Sang JM, Lockhart JL, Suarez A, et al. (1986). Female urinary incontinence: preoperative selection, surgical complications and results. J Urol.
1683 Prasopsanti K, Santi-Ngamkun A, Pornprasit K. (2007). Estimated cost of overactive bladder in Thailand. J Med Assoc Thai.
1684 Prati A, Cantoni C, Potenzoni D. (1992). Use of rociverine in patients with motor urge incontinence: A cystomanometric study of dose-effect correlations. Current Therapeutic Research, Clinical & Experimental.
1685 Pregazzi R, Sartore A, Bortoli P, et al. (2002). Immediate postpartum perineal examination as a predictor of puerperal pelvic floor dysfunction. Obstet Gynecol.
1686 Pregazzi R, Sartore A, Troiano L, et al. (2002). Postpartum urinary symptoms: prevalence and risk factors. Eur J Obstet Gynecol Reprod Biol.
1687 Preminger GM, Kettelhut MC, Elkins SL, et al. (1989). Ureteral stenting during extracorporeal shock wave lithotripsy: help or hindrance?. J Urol.
1688 Pressman MR, Figueroa WG, Kendrick-Mohamed J, et al. (1996). Nocturia. A rarely recognized symptom of sleep apnea and other occult sleep disorders. Arch Intern Med.
1689 Primus G. (1992). Maximal electrical stimulation in neurogenic detrusor hyperactivity: experiences in multiple sclerosis. Eur J Med.
1690 Primus G, Kramer G. (1996). Maximal external electrical stimulation for treatment of neurogenic or non-neurogenic urgency and/or urge incontinence. Neurourol Urodyn.
1691 Primus G, Pummer K. (1990). Oxybutynin hydrochloride in the management of detrusor instability. Int Urol Nephrol.
1692 Pron G, Bennett J, Common A, et al. (2003). The Ontario Uterine Fibroid Embolization Trial. Part 2. Uterine fibroid reduction and symptom relief after uterine artery embolization for fibroids. Fertil Steril.
1693 Pron G, Cohen M, Soucie J, et al. (2003). The Ontario Uterine Fibroid Embolization Trial. Part 1. Baseline patient characteristics, fibroid burden, and impact on life. Fertil Steril.
1694 Propert KJ, Schaeffer AJ, Brensinger CM, et al. (2000). A prospective study of interstitial cystitis: results of longitudinal followup of the interstitial cystitis data base cohort. The Interstitial Cystitis Data Base Study Group. J Urol.
1695 Pryor JL, Jenkins AD. (1990). Use of double-pigtail stents in extracorporeal shock wave lithotripsy. J Urol.
1696 Pryor JL, Langley MJ, Jenkins AD. (1991). Comparison of symptom characteristics of indwelling ureteral catheters. J Urol.
1697 Quarto G, Autorino R, Gallo A, et al. (2007). Quality of life in women with multiple sclerosis and overactive bladder syndrome. Int Urogynecol J Pelvic Floor Dysfunct.
1698 Quinn M. (2004). Obstetric denervation-gynaecological reinnervation: disruption of the inferior hypogastric plexus in childbirth as a source of gynaecological symptoms. Med Hypotheses.
1699 Quinn P, Goka J, Richardson H. (2003). Assessment of an electronic daily diary in patients with overactive bladder. BJU Int.
1700 Qvist N, Kristensen ES, Nielsen KK, et al. (1986). Detrusor instability in children with recurrent urinary tract infection and/or enuresis. I. Clinical conditions and symptomatology. Urol Int.
1701 Qvist N, Nielsen KK, Kristensen ES, et al. (1986). Detrusor instability in children with recurrent urinary tract infection and/or enuresis. II. Treatment. Urol Int.
1702 Rabey JM, Moriel EZ, Farkas A, et al. (1979). Detrusor hyperreflexia in multiple sclerosis. Alleviation by a combination of imipramine and propantheline, a clinico-laboratory study. Eur Neurol.
1703 Rackley R, Weiss JP, Rovner ES, et al. (2006). Nighttime dosing with tolterodine reduces overactive bladder-related nocturnal micturitions in patients with overactive bladder and nocturia. Urology.
1704 Radej M, Hitrec V, Krivec O, et al. (1976). Functional and tonometrical investigation of bladder and urethra in patients with stress incontinence. J Urol.
1705 Radley SC, Chapple CR, Mitsogiannis IC, et al. (2001). Transurethral implantation of macroplastique for the treatment of female stress urinary incontinence secondary to urethral sphincter deficiency. Eur Urol.
1706 Radley SC, Rosario DJ, Chapple CR, et al. (2001). Conventional and ambulatory urodynamic findings in women with symptoms suggestive of bladder overactivity. J Urol.
1707 Radomski SB, Caley B, Reiz JL, et al. (2004). Preliminary evaluation of a new controlled-release oxybutynin in urinary incontinence. Curr Med Res Opin.
1708 Radomski SB, Herschorn S. (1996). Laparoscopic Burch bladder neck suspension: early results. J Urol.
1709 Raes A, Hoebeke P, Segaert I, et al. (2004). Retrospective analysis of efficacy and tolerability of tolterodine in children with overactive bladder. Eur Urol.
1710 Rahmanou P, Chaliha C, Kulinskaya E, et al. (2008). Reliability testing of urodynamics, pressure flow studies and cough leak point pressure in women with urodynamic stress incontinence with and without detrusor overactivity. Int Urogynecol J Pelvic Floor Dysfunct.
1711 Rajan L. (1994). The impact of obstetric procedures and analgesia/anaesthesia during labour and delivery on breast feeding. Midwifery.
1712 Rajkumar GN, Small DR, Mustafa AW, et al. (2005). A prospective study to evaluate the safety, tolerability, efficacy and durability of response of intravesical injection of botulinum toxin type A into detrusor muscle in patients with refractory idiopathic detrusor overactivity. BJU Int.
1713 Ramahi AJ, Richardson DA. (1990). A practical approach to the painful bladder syndrome. J Reprod Med.
1714 Ramamurthy HR, Kanitkar M. (2008). Recurrent urinary tract infection and functional voiding disorders. Indian Pediatr.
1715 Ramon J, Mekras J, Webster GD. (1991). Transvaginal needle suspension procedures for recurrent stress incontinence. Urology.
1716 Ramsay IN, Clancy S, Hilton P. (1992). Subtrigonal phenol injections in the treatment of idiopathic detrusor instability in the female--a long-term urodynamic follow-up. Br J Urol.
1717 Ramsay-Olocco K, Alexandrova L, Nellore R, et al. (2004). Pre-clinical and clinical evaluation of solution and soft gelatin capsule formulations for a BCS class 3 compound with atypical physicochemical properties. J Pharm Sci.
1718 Ramsden PD, Smith JC, Dunn M, et al. (1976). Distension therapy for the unstable bladder: later results including an assessment of repeat distensions. Br J Urol.
1719 Raney B, Heyn R, Hays DM, et al. (1993). Sequelae of treatment in 109 patients followed for 5 to 15 years after diagnosis of sarcoma of the bladder and prostate. A report from the Intergroup Rhabdomyosarcoma Study Committee. Cancer.
1720 Ransmayr GN, Holliger S, Schletterer K, et al. (2008). Lower urinary tract symptoms in dementia with Lewy bodies, Parkinson disease, and Alzheimer disease. Neurology.
1721 Rapidi CA, Petropoulou K, Galata A, et al. (2008). Neuropathic bladder dysfunction in patients with motor complete and sensory incomplete spinal cord lesion. Spinal Cord.
1722 Rapp DE, Lucioni A, Katz EE, et al. (2004). Use of botulinum-A toxin for the treatment of refractory overactive bladder symptoms: an initial experience. Urology.
1723 Rardin CR, Rosenblatt PL, Kohli N, et al. (2002). Release of tension-free vaginal tape for the treatment of refractory postoperative voiding dysfunction. Obstet Gynecol.
1724 Rasmussen KL, Krue S, Johansson LE, et al. (1997). Obesity as a predictor of postpartum urinary symptoms. Acta Obstet Gynecol Scand.
1725 Rasuli P, Hammond I, Al-Mutairi B, et al. (2008). Spherical versus conventional polyvinyl alcohol particles for uterine artery embolization. J Vasc Interv Radiol.
1726 Raza-Khan F, Graziano S, Kenton K, et al. (2006). Peripartum urinary incontinence in a racially diverse obstetrical population. Int Urogynecol J Pelvic Floor Dysfunct.
1727 Reese PR, Pleil AM, Okano GJ, et al. (2003). Multinational study of reliability and validity of the King’s Health Questionnaire in patients with overactive bladder. Qual Life Res.
1728 Reeves P, Irwin D, Kelleher C, et al. (2006). The current and future burden and cost of overactive bladder in five European countries. Eur Urol.
1729 Reid GC, DeLancey JO, Hopkins MP, et al. (1990). Urinary incontinence following radical vulvectomy. Obstet Gynecol.
1730 Reiertsen O, Kulseng-Hanssen S. (1983). Simultaneous urethrocystometry in gynaecological patients with lower urinary tract dysfunction. Ann Chir Gynaecol.
1731 Reinberg Y, Crocker J, Wolpert J, et al. (2003). Therapeutic efficacy of extended release oxybutynin chloride, and immediate release and long acting tolterodine tartrate in children with diurnal urinary incontinence. J Urol.
1732 Reitz A, Denys P, Fermanian C, et al. (2007). Do repeat intradetrusor botulinum toxin type a injections yield valuable results? Clinical and urodynamic results after five injections in patients with neurogenic detrusor overactivity. Eur Urol.
1733 Reitz A, Stohrer M, Kramer G, et al. (2004). European experience of 200 cases treated with botulinum-A toxin injections into the detrusor muscle for urinary incontinence due to neurogenic detrusor overactivity. Eur Urol.
1734 Resnick NM, Yalla SV, Laurino E. (1989). The pathophysiology of urinary incontinence among institutionalized elderly persons. N Engl J Med.
1735 Rezapour M, Ulmsten U. (2001). Tension-Free vaginal tape (TVT) in women with mixed urinary incontinence--a long-term follow-up. Int Urogynecol J Pelvic Floor Dysfunct.
1736 Ricci JA, Baggish JS, Hunt TL, et al. (2001). Coping strategies and health care-seeking behavior in a US national sample of adults with symptoms suggestive of overactive bladder. Clin Ther.
1737 Richmond D. (1993). The incontinent woman: 2. Br J Hosp Med.
1738 Richter HE, Diokno A, Kenton K, et al. (2008). Predictors of treatment failure 24 months after surgery for stress urinary incontinence. J Urol.
1739 Richter HE, Goode PS, Brubaker L, et al. (2008). Two-year outcomes after surgery for stress urinary incontinence in older compared with younger women. Obstet Gynecol.
1740 Richter HE, Varner RE, Sanders E, et al. (2001). Effects of pubovaginal sling procedure on patients with urethral hypermobility and intrinsic sphincteric deficiency: would they do it again?. Am J Obstet Gynecol.
1741 Ridley DM. (1988). Urinary urge incontinence--selection of patients for surgery. S Afr Med J.
1742 Rigby D. (1996). Promoting continence with electrostimulation. Prof Nurse.
1743 Riss PA, Koelbl H. (1988). The predictive values of single and combined urodynamic parameters. Acta Obstet Gynecol Scand.
1744 Ritchie RW, Lindfield DM, Lockyer CR, et al. (2008). Ocular side-effects of urological pharmacy. BJU Int.
1745 Riva D, Casolati E. (1984). Oxybutynin chloride in the treatment of female idiopathic bladder instability. Results from double blind treatment. Clin Exp Obstet Gynecol.
1746 Robb-Nicholson C. (2008). By the way, doctor. I’m 80 and suffer from an overactive bladder that hasn’t responded to the usual treatments. My urologist is recommending an Interstim neuromodulator. What are the pros and cons of this therapy?. Harv Womens Health Watch.
1747 Robertson AS, Davies JB, Webb RJ, et al. (1991). Bladder augmentation and replacement. Urodynamic and clinical review of 25 patients. Br J Urol.
1748 Robertson AS, Griffiths C, Neal DE. (1996). Conventional urodynamics and ambulatory monitoring in the definition and management of bladder outflow obstruction. J Urol.
1749 Robertson AS, Griffiths CJ, Ramsden PD, et al. (1994). Bladder function in healthy volunteers: ambulatory monitoring and conventional urodynamic studies. Br J Urol.
1750 Robinson D, Anders K, Cardozo L, et al. (2007). Outcome measures in urogynaecology: the clinicians’ perspective. Int Urogynecol J Pelvic Floor Dysfunct.
1751 Robinson D, Anders K, Cardozo L, et al. (2002). Can ultrasound replace ambulatory urodynamics when investigating women with irritative urinary symptoms?. BJOG.
1752 Robinson JM, Brocklehurst JC. (1983). Emepronium bromide and flavoxate hydrochloride in the treatment of urinary incontinence associated with detrusor instability in elderly women. Br J Urol.
1753 Robson WL, Leung AK. (1993). Extraordinary urinary frequency syndrome. Urology.
1754 Rodhe N, Englund L, Molstad S, et al. (2008). Bacteriuria is associated with urge urinary incontinence in older women. Scand J Prim Health Care.
1755 Rodrigues P, Hering F, Meler A, et al. (2004). Pubo-fascial versus vaginal sling operation for the treatment of stress urinary incontinence: a prospective study. Neurourol Urodyn.
1756 Rodriguez LV, Berman J, Raz S. (2001). Polypropylene sling for treatment of stress urinary incontinence: an alternative to tension-free vaginal tape. Tech Urol.
1757 Rodriguez LV, Bukkapatnam R, Shah SM, et al. (2005). Transvaginal paravaginal repair of high-grade cystocele central and lateral defects with concomitant suburethral sling: report of early results, outcomes, and patient satisfaction with a new technique. Urology.
1758 Rodriguez LV, de Almeida F, Dorey F, et al. (2004). Does Valsalva leak point pressure predict outcome after the distal urethral polypropylene sling? Role of urodynamics in the sling era. J Urol.
1759 Rohr G, Kragstrup J, Gaist D, et al. (2004). Genetic and environmental influences on urinary incontinence: a Danish population-based twin study of middle-aged and elderly women. Acta Obstet Gynecol Scand.
1760 Romancik M, Lutter I, Goncalves F, et al. (2006). Valsalva leak point pressure predicts outcome after transobturator suburethral tape implantation--fact or fiction?. Bratisl Lek Listy.
1761 Romanzi LJ, Chaikin DC, Blaivas JG. (1999). The effect of genital prolapse on voiding. J Urol.
1762 Romanzi LJ, Groutz A, Heritz DM, et al. (2001). Involuntary detrusor contractions: correlation of urodynamic data to clinical categories. Neurourol Urodyn.
1763 Rombis V, Triantafyllidis A, Balaxis E, et al. (2005). Nocturnal enuresis in children. A four-year experience in outpatient clinics of pediatric urology. Folia Med (Plovdiv).
1764 Roongruangsilp U, Lertsithichai P, Kochakarn W, et al. (2005). Correlation between symptoms and urodynamic findings in Thai female patients with urinary incontinence. J Med Assoc Thai.
1765 Roovers JP, van der Bom JG, Huub van der Vaart C, et al. (2001). Does mode of hysterectomy influence micturition and defecation?. Acta Obstet Gynecol Scand.
1766 Roovers JP, van der Vaart CH, van der Bom JG, et al. (2004). A randomised controlled trial comparing abdominal and vaginal prolapse surgery: effects on urogenital function. BJOG.
1767 Roovers JP, van Laar JO, Loffeld C, et al. (2007). Does urodynamic investigation improve outcome in patients undergoing prolapse surgery?. Neurourol Urodyn.
1768 Rortveit G, Daltveit AK, Hannestad YS, et al. (2003). Vaginal delivery parameters and urinary incontinence: the Norwegian EPINCONT study. Am J Obstet Gynecol.
1769 Rortveit G, Hannestad YS, Daltveit AK, et al. (2001). Age- and type-dependent effects of parity on urinary incontinence: the Norwegian EPINCONT study. Obstet Gynecol.
1770 Rosario DJ, Smith DJ, Radley SC, et al. (1999). Pharmacodynamics of anticholinergic agents measured by ambulatory urodynamic monitoring: a study of methodology. Neurourol Urodyn.
1771 Rose AE, Payne CK, Azevedo K. (2005). Pilot study of the feasibility of in-office bladder distention using electromotive drug adminstration (EMDA). Neurourol Urodyn.
1772 Rosen LS, Brown J, Laxa B, et al. (2003). Phase I study of TLK286 (glutathione S-transferase P1–1 activated glutathione analogue) in advanced refractory solid malignancies. Clin Cancer Res.
1773 Rosen RC, Coyne KS, Henry D, et al. (2008). Beyond the cluster: methodological and clinical implications in the Boston Area Community Health survey and EPIC studies. BJU Int.
1774 Rosenberg LJ, Griffiths DJ, Resnick NM. (2005). Factors that distinguish continent from incontinent older adults with detrusor overactivity. J Urol.
1775 Rosenberg MJ, Rochat RW, Akbar J, et al. (1982). Sterilization in Bangladesh: mortality, morbidity, and risk factors. Int J Gynaecol Obstet.
1776 Rosenblum N, Scarpero HM, Nitti VW. (2004). Voiding dysfunction in young, nulliparous women: symptoms and urodynamic findings. Int Urogynecol J Pelvic Floor Dysfunct.
1777 Ross JW. (1997). Techniques of laparoscopic repair of total vault eversion after hysterectomy. J Am Assoc Gynecol Laparosc.
1778 Ross JW. (2001). Laparoscopic Burch colposuspension and overlapping sphincteroplasty for double incontinence. JSLS.
1779 Rosser CJ, Slaton JW, Izawa JI, et al. (2003). Clinical presentation and outcome of high-grade urinary bladder leiomyosarcoma in adults. Urology.
1780 Rost A, Fiedler U, Fester C. (1979). Comparative analysis of the results of suspension-urethroplasty according to Marshall-Marchetti-Krantz and of urethrovesicopexy with adhesive. Urol Int.
1781 Rotman M, Aziz H, Porrazzo M, et al. (1990). Treatment of advanced transitional cell carcinoma of the bladder with irradiation and concomitant 5-fluorouracil infusion. Int J Radiat Oncol Biol Phys.
1782 Roupret M, Chartier-Kastler E, Almeras C, et al. (2004). Sacral neuromodulation for refractory detrusor overactivity in women with an artificial urinary sphincter. J Urol.
1783 Rovner ES, Rackley R, Nitti VW, et al. (2008). Tolterodine extended release is efficacious in continent and incontinent subjects with overactive bladder. Urology.
1784 Ruarte AC, Podesta ML, Medel R. (2002). Detrusor after-contractions in children with normal urinary tracts. BJU Int.
1785 Ruffion A, Capelle O, Paparel P, et al. (2006). What is the optimum dose of type A botulinum toxin for treating neurogenic bladder overactivity?. BJU Int.
1786 Rufford J, Cardozo L. (2004). Urethral diverticula: a diagnostic dilemma. BJU Int.
1787 Rufford J, Hextall A, Cardozo L, et al. (2003). A double-blind placebo-controlled trial on the effects of 25 mg estradiol implants on the urge syndrome in postmenopausal women. Int Urogynecol J Pelvic Floor Dysfunct.
1788 Ruud Bosch JL, Groen J. (1996). Treatment of refractory urge urinary incontinence with sacral spinal nerve stimulation in multiple sclerosis patients. Lancet.
1789 Sackley CM, Rodriguez NA, van den Berg M, et al. (2008). A phase II exploratory cluster randomized controlled trial of a group mobility training and staff education intervention to promote urinary continence in UK care homes. Clin Rehabil.
1790 Safarinejad MR, Hosseini SY. (2006). Safety and efficacy of tramadol in the treatment of idiopathic detrusor overactivity: a double-blind, placebo-controlled, randomized study. Br J Clin Pharmacol.
1791 Safir MH, Gousse AE, Rovner ES, et al. (1999). 4-Defect repair of grade 4 cystocele. J Urol.
1792 Sahai A, Khan MS, Dasgupta P. (2007). Efficacy of botulinum toxin-A for treating idiopathic detrusor overactivity: results from a single center, randomized, double-blind, placebo controlled trial. J Urol.
1793 Sahai A, Khan MS, Le Gall N, et al. (2008). Urodynamic assessment of poor responders after botulinum toxin-A treatment for overactive bladder. Urology.
1794 Saini J, Axelrod FB, Maayan C, et al. (2003). Urinary incontinence in familial dysautonomia. Int Urogynecol J Pelvic Floor Dysfunct.
1795 Saito M, Kawatani M, Kinoshita Y, et al. (2005). Effectiveness of an anti-inflammatory drug, loxoprofen, for patients with nocturia. Int J Urol.
1796 Saito M, Kondo A, Kato K, et al. (1991). Bladder dysfunction due to human T-lymphotrophic virus type I associated myelopathy. Br J Urol.
1797 Saito M, Kondo A, Kato T, et al. (1993). Frequency-volume charts: comparison of frequency between elderly and adult patients. Br J Urol.
1798 Saito M, Tabuchi F, Otsubo K, et al. (2000). Treatment of overactive bladder with modified intravesical oxybutynin chloride. Neurourol Urodyn.
1799 Saito M, Watanabe T, Tabuchi F, et al. (2004). Urodynamic effects and safety of modified intravesical oxybutynin chloride in patients with neurogenic detrusor overactivity: 3 years experience. Int J Urol.
1800 Sakakibara R, Hattori T, Boku K, et al. (2000). Micturitional disturbance in neuro-Behcet’s syndrome. Auton Neurosci.
1801 Sakakibara R, Hattori T, Kita K, et al. (1998). Stress induced urinary incontinence in patients with spinocerebellar degeneration. J Neurol Neurosurg Psychiatry.
1802 Sakakibara R, Hattori T, Kuwabara S, et al. (1997). Micturitional disturbance in patients with Guillain-Barre syndrome. J Neurol Neurosurg Psychiatry.
1803 Sakakibara R, Hattori T, Kuwabara S, et al. (1998). Micturitional disturbance in patients with chronic inflammatory demyelinating polyneuropathy. Neurology.
1804 Sakakibara R, Hattori T, Uchiyama T, et al. (2001). Urinary dysfunction in Brown-Sequard syndrome. Neurourol Urodyn.
1805 Sakakibara R, Hattori T, Uchiyama T, et al. (2001). Neurogenic failures of the external urethral sphincter closure and relaxation; a videourodynamic study. Auton Neurosci.
1806 Sakakibara R, Hattori T, Yasuda K, et al. (1996). Micturition disturbance in acute transverse myelitis. Spinal Cord.
1807 Sakakibara R, Hattori T, Yasuda K, et al. (1996). Micturitional disturbance after acute hemispheric stroke: analysis of the lesion site by CT and MRI. J Neurol Sci.
1808 Sakakibara R, Hattori T, Yasuda K, et al. (1996). Micturitional disturbance and the pontine tegmental lesion: urodynamic and MRI analyses of vascular cases. J Neurol Sci.
1809 Sakakibara R, Hattori T, Yasuda K, et al. (1996). Micturitional disturbance in acute disseminated encephalomyelitis (ADEM). J Auton Nerv Syst.
1810 Sakakibara R, Hattori T, Yasuda K, et al. (1996). Micturitional disturbance in syringomyelia. J Neurol Sci.
1811 Sakakibara R, Ito T, Uchiyama T, et al. (2005). Lower urinary tract function in dementia of Lewy body type. J Neurol Neurosurg Psychiatry.
1812 Sakakibara R, Ito T, Uchiyama T, et al. (2008). Effects of milnacipran and paroxetine on overactive bladder due to neurologic diseases: a urodynamic assessment. Urol Int.
1813 Sakakibara R, Kanda T, Sekido T, et al. (2008). Mechanism of bladder dysfunction in idiopathic normal pressure hydrocephalus. Neurourol Urodyn.
1814 Sakakibara R, Shinotoh H, Uchiyama T, et al. (2001). Questionnaire-based assessment of pelvic organ dysfunction in Parkinson’s disease. Auton Neurosci.
1815 Sakakibara R, Uchiyama T, Arai K, et al. (2004). Lower urinary tract dysfunction in Machado-Joseph disease: a study of 11 clinical-urodynamic observations. J Neurol Sci.
1816 Sakakibara R, Uchiyama T, Awa Y, et al. (2007). Psychogenic urinary dysfunction: a uro-neurological assessment. Neurourol Urodyn.
1817 Sakakibara R, Uchiyama T, Liu Z, et al. (2005). Nocturnal polyuria with abnormal circadian rhythm of plasma arginine vasopressin in post-stroke patients. Intern Med.
1818 Sakakibara R, Uchiyama T, Yamanishi T, et al. (2004). Urinary function in patients with corticobasal degeneration; comparison with normal subjects. Neurourol Urodyn.
1819 Sakakibara R, Uchiyama T, Yoshiyama M, et al. (2005). Preliminary communication: urodynamic assessment of donepezil hydrochloride in patients with Alzheimer’s disease. Neurourol Urodyn.
1820 Sale PG, Wyman JF. (1994). Achievement of goals associated with bladder training by older incontinent women. Appl Nurs Res.
1821 Salonia A, Zanni G, Nappi RE, et al. (2004). Sexual dysfunction is common in women with lower urinary tract symptoms and urinary incontinence: results of a cross-sectional study. Eur Urol.
1822 Salvatore S, Khullar V, Cardozo L, et al. (2001). Evaluating ambulatory urodynamics: a prospective study in asymptomatic women. BJOG.
1823 Sammour ZM, Gomes CM, Duarte RJ, et al. (2006). Voiding dysfunction and the Williams-Beuren syndrome: a clinical and urodynamic investigation. J Urol.
1824 Samuel M, Boddy SA, Wang K. (2001). What happens to the bladder at night? Overnight urodynamic monitoring in children with neurogenic vesical dysfunction. J Urol.
1825 Sand PK. (1996). Pelvic floor stimulation in the treatment of mixed incontinence complicated by a low-pressure urethra. Obstet Gynecol.
1826 Sand PK, Appell R. (2006). Disruptive effects of overactive bladder and urge urinary incontinence in younger women. Am J Med.
1827 Sand PK, Bowen LW, Ostergard DR. (1990). The prognostic significance of augmentation of urethral closure pressure and functional length. Int J Gynaecol Obstet.
1828 Sand PK, Brubaker LT, Novak T. (1991). Simple standing incremental cystometry as a screening method for detrusor instability. Obstet Gynecol.
1829 Sand PK, Hill RC, Ostergard DR. (1987). Supine urethroscopic and standing cystometry as screening methods for the detection of detrusor instability. Obstet Gynecol.
1830 Sand PK, Hill RC, Ostergard DR. (1988). Incontinence history as a predictor of detrusor stability. Obstet Gynecol.
1831 Sandvik H, Hunskaar S, Vanvik A, et al. (1995). Diagnostic classification of female urinary incontinence: an epidemiological survey corrected for validity. J Clin Epidemiol.
1832 Sandvik H, Kveine E, Hunskaar S. (1993). Female urinary incontinence--psychosocial impact, self care, and consultations. Scand J Caring Sci.
1833 Sangthawan D, Watthanaarpornchai S, Phungrassami T. (2001). Randomized double blind, placebo-controlled study of pilocarpine administered during head and neck irradiation to reduce xerostomia. J Med Assoc Thai.
1834 Satoh A, Hanawa Y, Nakamura S. (2004). Clinical study of bladder cancer: Proteinuria as a predictor of recurrence and efficacy of intravesical bacille Calmette-Guerin therapy. Int J Urol.
1835 Sau G, Siracusano S, Aiello I, et al. (1999). The usefulness of the somatosensory evoked potentials of the pudendal nerve in diagnosis of probable multiple sclerosis. Spinal Cord.
1836 Sau GF, Aiello I, Siracusano S, et al. (1997). Pudendal nerve somatosensory evoked potentials in probable multiple sclerosis. Ital J Neurol Sci.
1837 Saw AH. (1990). Management of urinary tract infection and vesico-ureteric reflux in children. Singapore Med J.
1838 Scarpero HM, Dmochowski RR, Nitti VW. (2003). Repeat urethrolysis after failed urethrolysis for iatrogenic obstruction. J Urol.
1839 Schaer GN, Koechli OR, Schuessler B, et al. (1995). Improvement of perineal sonographic bladder neck imaging with ultrasound contrast medium. Obstet Gynecol.
1840 Schaer GN, Koechli OR, Schuessler B, et al. (1996). Usefulness of ultrasound contrast medium in perineal sonography for visualization of bladder neck funneling--first observations. Urology.
1841 Schaffer JI, Bloom SL, Casey BM, et al. (2005). A randomized trial of the effects of coached vs uncoached maternal pushing during the second stage of labor on postpartum pelvic floor structure and function. Am J Obstet Gynecol.
1842 Scheepens WA, de Bie RA, Weil EH, et al. (2002). Unilateral versus bilateral sacral neuromodulation in patients with chronic voiding dysfunction. J Urol.
1843 Scheepens WA, Jongen MM, Nieman FH, et al. (2002). Predictive factors for sacral neuromodulation in chronic lower urinary tract dysfunction. Urology.
1844 Scheepens WA, Van Koeveringe GA, De Bie RA, et al. (2002). Long-term efficacy and safety results of the two-stage implantation technique in sacral neuromodulation. BJU Int.
1845 Schewe J, Brands FH, Pannek J. (2002). Voiding dysfunction in children: role of urodynamic studies. Urol Int.
1846 Schimpf MO, O’Sullivan DM, LaSala CA, et al. (2007). Anterior vaginal wall prolapse and voiding dysfunction in urogynecology patients. Int Urogynecol J Pelvic Floor Dysfunct.
1847 Schober JM, Lipman R, Haltigan JD, et al. (2004). The impact of monosymptomatic nocturnal enuresis on attachment parameters. Scand J Urol Nephrol.
1848 Schofield EC, Clausen JA, Burcher E, et al. (2005). GAP-43 immunoreactivity of subepithelial and detrusor muscle nerve fibres in patients with refractory idiopathic detrusor overactivity. Neurourol Urodyn.
1849 Scholtmeijer RJ. (1991). Treatment of vesicoureteric reflux: results after 3 years in a prospective study. Child Nephrol Urol.
1850 Scholtmeijer RJ. (1993). Treatment of vesicoureteric reflux. Results of a prospective study. Br J Urol.
1851 Scholtmeijer RJ, Griffiths DJ. (1988). Treatment of vesicoureteric reflux. Preliminary report of a prospective study. Br J Urol.
1852 Scholtmeijer RJ, van Mastrigt R. (1991). The effect of oxyphenonium bromide and oxybutynin hydrochloride on detrusor contractility and reflux in children with vesicoureteral reflux and detrusor instability. J Urol.
1853 Schostak M, Miller K, Muller M, et al. (2002). Transvaginal bone anchors in female stress urinary incontinence: poor results. Gynecol Obstet Invest.
1854 Schrepferman CG, Griebling TL, Nygaard IE, et al. (2000). Resolution of urge symptoms following sling cystourethropexy. J Urol.
1855 Schulman SL, Zderic S, Kaplan P. (1996). Increased prevalence of urinary symptoms and voiding dysfunction in Williams syndrome. J Pediatr.
1856 Schulte-Baukloh H, Knispel HH, Stolze T, et al. (2005). Repeated botulinum-A toxin injections in treatment of children with neurogenic detrusor overactivity. Urology.
1857 Schulte-Baukloh H, Schobert J, Stolze T, et al. (2006). Efficacy of botulinum-A toxin bladder injections for the treatment of neurogenic detrusor overactivity in multiple sclerosis patients: an objective and subjective analysis. Neurourol Urodyn.
1858 Schulte-Baukloh H, Weiss C, Stolze T, et al. (2005). Botulinum-A toxin detrusor and sphincter injection in treatment of overactive bladder syndrome: objective outcome and patient satisfaction. Eur Urol.
1859 Schulte-Baukloh H, Weiss C, Stolze T, et al. (2005). Botulinum-A toxin for treatment of overactive bladder without detrusor overactivity: urodynamic outcome and patient satisfaction. Urology.
1860 Schultheiss D, Hofner K, Oelke M, et al. (1998). Does bone anchor fixation improve the outcome of percutaneous bladder neck suspension in female stress urinary incontinence?. Br J Urol.
1861 Schurch B, de Seze M, Denys P, et al. (2005). Botulinum toxin type a is a safe and effective treatment for neurogenic urinary incontinence: results of a single treatment, randomized, placebo controlled 6-month study. J Urol.
1862 Schurch B, Denys P, Kozma CM, et al. (2007). Reliability and validity of the Incontinence Quality of Life questionnaire in patients with neurogenic urinary incontinence. Arch Phys Med Rehabil.
1863 Schurch B, Denys P, Kozma CM, et al. (2007). Botulinum toxin A improves the quality of life of patients with neurogenic urinary incontinence. Eur Urol.
1864 Schurch B, Reitz A, Tenti G. (2004). Electromotive drug administration of lidocaine to anesthetize the bladder before botulinum-A toxin injections into the detrusor. Spinal Cord.
1865 Schurch B, Stohrer M, Kramer G, et al. (2000). Botulinum-A toxin for treating detrusor hyperreflexia in spinal cord injured patients: a new alternative to anticholinergic drugs? Preliminary results. J Urol.
1866 Scotti RJ, Angell G, Flora R, et al. (1998). Antecedent history as a predictor of surgical cure of urgency symptoms in mixed incontinence. Obstet Gynecol.
1867 Sears CL, Wright J, O’Brien J, et al. (2009). The racial distribution of female pelvic floor disorders in an equal access health care system. J Urol.
1868 Seckiner I, Yesilli C, Mungan NA, et al. (2007). Correlations between the ICIQ-SF score and urodynamic findings. Neurourol Urodyn.
1869 Segal J, Steele A, Vassallo B, et al. (2006). Various surgical approaches to treat voiding dysfunction following anti-incontinence surgery. Int Urogynecol J Pelvic Floor Dysfunct.
1870 Segal JL, Vassallo B, Kleeman S, et al. (2004). Prevalence of persistent and de novo overactive bladder symptoms after the tension-free vaginal tape. Obstet Gynecol.
1871 Segal JL, Vassallo BJ, Kleeman SD, et al. (2006). The efficacy of the tension-free vaginal tape in the treatment of five subtypes of stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
1872 Seim A, Sivertsen B, Eriksen BC, et al. (1996). Treatment of urinary incontinence in women in general practice: observational study. BMJ.
1873 Seki N, Masuda K, Kinukawa N, et al. (2004). Risk factors for febrile urinary tract infection in children with myelodysplasia treated by clean intermittent catheterization. Int J Urol.
1874 Sekido N, Hinotsu S, Kawai K, et al. (2006). How many uncomplicated male and female overactive bladder patients reveal detrusor overactivity during urodynamic study?. Int J Urol.
1875 Sellors JW, Pickard L, Gafni A, et al. (1992). Effectiveness and efficiency of selective vs universal screening for chlamydial infection in sexually active young women. Arch Intern Med.
1876 Sen I, Onaran M, Tan MO, et al. (2007). Evaluation of sexual function in women with overactive bladder syndrome. Urol Int.
1877 Sensirivatana R, Watana D, Sornmani W, et al. (1987). Diagnostic study of urinary frequency in children. Urology.
1878 Serels S, Stein M. (1998). Prospective study comparing hyoscyamine, doxazosin, and combination therapy for the treatment of urgency and frequency in women. Neurourol Urodyn.
1879 Serels SR, Rackley RR, Appell RA. (2000). Surgical treatment for stress urinary incontinence associated with valsalva induced detrusor instability. J Urol.
1880 Serra DB, Affrime MB, Bedigian MP, et al. (2005). QT and QTc interval with standard and supratherapeutic doses of darifenacin, a muscarinic M3 selective receptor antagonist for the treatment of overactive bladder. J Clin Pharmacol.
1881 Sethia KK, Smith JC. (1987). The effect of pH and lignocaine on detrusor instability. Br J Urol.
1882 Sethia KK, Webb RJ, Neal DE. (1991). Urodynamic study of ileocystoplasty in the treatment of idiopathic detrusor instability. Br J Urol.
1883 Setiati S, Santoso BI, Istanti R. (2006). Estimating the annual cost of overactive bladder in Indonesia. Acta Med Indones.
1884 Sevestre S, Ciofu C, Deval B, et al. (2003). Results of the tension-free vaginal tape technique in the elderly. Eur Urol.
1885 Shafik A, El Sibai O, Shafik AA, et al. (2004). Vesical pacing: pacing parameters required for normalization of vesical electric activity in patients with overactive bladder. Front Biosci.
1886 Shafik A, El-Sibai O, Shafik AA, et al. (2004). The electrovesicogram in the overactive bladder: role in determining pathogenesis and diagnostic significance. Urol Res.
1887 Shafik A, Shafik I, el-Sibai O, et al. (2004). Vesical pacing in patients with overactive bladder: technique and results. Int Urol Nephrol.
1888 Shafik A, Shafik IA. (2003). Overactive bladder inhibition in response to pelvic floor muscle exercises. World J Urol.
1889 Shaker HS, Hassouna M. (1998). Sacral nerve root neuromodulation: an effective treatment for refractory urge incontinence. J Urol.
1890 Shapiro T, Dalton M, Hammock J, et al. (2005). The prevalence of urinary tract infections and sexually transmitted disease in women with symptoms of a simple urinary tract infection stratified by low colony count criteria. Acad Emerg Med.
1891 Sharma S, Albertazzi P, Bottazzi M. (2007). The long-term effect of raloxifene on the genitourinary tract. Climacteric.
1892 Shaw C, Gupta RD, Bushnell DM, et al. (2006). The extent and severity of urinary incontinence amongst women in UK GP waiting rooms. Fam Pract.
1893 Shaya FT, Blume S, Gu A, et al. (2005). Persistence with overactive bladder pharmacotherapy in a Medicaid population. Am J Manag Care.
1894 Shelbaia AM, Hashish NM. (2007). Limited experience in early management of genitourinary tract fistulas. Urology.
1895 Sheremata WA, Harrington WJ, Bradshaw PA, et al. (1993). Association of ‘(tropical) ataxic neuropathy’ with HTLV-II. Virus Res.
1896 Sherman ND, Jamison MG, Webster GD, et al. (2005). Sacral neuromodulation for the treatment of refractory urinary urge incontinence after stress incontinence surgery. Am J Obstet Gynecol.
1897 Shibasaki H, Endo C, Kuroda Y, et al. (1988). Clinical picture of HTLV-I associated myelopathy. J Neurol Sci.
1898 Shima H, Mori Y, Nojima M, et al. (1998). Lower urinary tract problems in patients with enuresis. Eur Urol.
1899 Shimabukuro T, Naito K. (2007). Evaluation of lower urinary tract symptoms and how bothersome it was with or without urinary incontinence in apparently healthy persons of both sexes. Hinyokika Kiyo.
1900 Shimonovitz S, Monga AK, Stanton SL. (1997). Does the menstrual cycle influence cystometry?. Int Urogynecol J Pelvic Floor Dysfunct.
1901 Shin JC, Kim YW, Park CI, et al. (2006). Effect of the intravesical resiniferatoxin instillation evaluated by the ice provocative urodynamic study. Spinal Cord.
1902 Shinopulos NM, Jacobson J. (1999). Relationship between health promotion lifestyle profiles and patient outcomes of biofeedback therapy for urinary incontinence. Urol Nurs.
1903 Shoukry MS, El Salmy S, Aly GA, et al. (1998). Urodynamic predictors of upper tract deterioration in children with myelodysplasia. Scand J Urol Nephrol.
1904 Shull BL, Baden WF. (1989). A six-year experience with paravaginal defect repair for stress urinary incontinence. Am J Obstet Gynecol.
1905 Siami P, Seidman LS, Lama D. (2002). A multicenter, prospective, open-label study of tolterodine extended-release 4 mg for overactive bladder: the speed of onset of therapeutic assessment trial (STAT). Clin Ther.
1906 Siddiqui K, Raj H, Flynn RJ, et al. (2008). Minimally invasive treatment of female stress urinary incontinence: 100 cases using SPARC sling. Ir J Med Sci.
1907 Siddiqui MA, Perry CM, Scott LJ. (2004). Oxybutynin extended-release: a review of its use in the management of overactive bladder. Drugs.
1908 Siegel SW, Richardson DA, Miller KL, et al. (1997). Pelvic floor electrical stimulation for the treatment of urge and mixed urinary incontinence in women. Urology.
1909 Sievert KD, Nagele U, Pannek J, et al. (2007). Subcutaneous tunneling of the temporary testing electrode significantly improves the success rate of subchronic sacral nerve modulation (SNM). World J Urol.
1910 Siltberg H, Larsson G, Victor A. (1997). Frequency/volume chart: the basic tool for investigating urinary symptoms. Acta Obstet Gynecol Scand Suppl.
1911 Silva C, Avelino A, Souto-Moura C, et al. (2001). A light- and electron-microscopic histopathological study of human bladder mucosa after intravesical resiniferatoxin application. BJU Int.
1912 Silva C, Ribeiro MJ, Cruz F. (2002). The effect of intravesical resiniferatoxin in patients with idiopathic detrusor instability suggests that involuntary detrusor contractions are triggered by C-fiber input. J Urol.
1913 Silva C, Rio ME, Cruz F. (2000). Desensitization of bladder sensory fibers by intravesical resiniferatoxin, a capsaicin analog: long-term results for the treatment of detrusor hyperreflexia. Eur Urol.
1914 Silva C, Silva J, Ribeiro MJ, et al. (2005). Urodynamic effect of intravesical resiniferatoxin in patients with neurogenic detrusor overactivity of spinal origin: results of a double-blind randomized placebo-controlled trial. Eur Urol.
1915 Silva-Filho AL, Candido EB, Noronha A, et al. (2006). Comparative study of autologous pubovaginal sling and synthetic transobturator (TOT) SAFYRE sling in the treatment of stress urinary incontinence. Arch Gynecol Obstet.
1916 Simeonova Z, Bengtsson C. (1990). Prevalence of urinary incontinence among women at a Swedish primary health care centre. Scand J Prim Health Care.
1917 Singh G, Thomas DG. (1996). Artificial urinary sphincter in patients with neurogenic bladder dysfunction. Br J Urol.
1918 Sinha D, Blackwell A, Moran PA. (2008). Outcome measures after TVT for mixed urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
1919 Sinha D, Nallaswamy V, Arunkalaivanan AS. (2006). Value of leak point pressure study in women with incontinence. J Urol.
1920 Sivaslioglu AA, Caliskan E, Dolen I, et al. (2007). A randomized comparison of transobturator tape and Burch colposuspension in the treatment of female stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
1921 Skala C, Emons G, Krauss T, et al. (2004). Postoperative funneling after anti-incontinence surgery--a prognostic indicator?--Part 1: colposuspension. Neurourol Urodyn.
1922 Skeil D, Thorpe AC. (2001). Transcutaneous electrical nerve stimulation in the treatment of neurological patients with urinary symptoms. BJU Int.
1923 Slors FJ, van Zuijlen PP, van Dijk GJ. (2000). Sexual and bladder dysfunction after total mesorectal excision for benign diseases. Scand J Gastroenterol Suppl.
1924 Smet PJ, Moore KH, Jonavicius J. (1997). Distribution and colocalization of calcitonin gene-related peptide, tachykinins, and vasoactive intestinal peptide in normal and idiopathic unstable human urinary bladder. Lab Invest.
1925 Smith CP, Nishiguchi J, O’Leary M, et al. (2005). Single-institution experience in 110 patients with botulinum toxin A injection into bladder or urethra. Urology.
1926 Smith DA, Ouslander JG. (2000). Pharmacologic management of urinary incontinence in older adults. Topics in Geriatric Rehabilitation.
1927 Smith DB, Boileau MA, Buan LD. (2000). A self-directed home biofeedback system for women with symptoms of stress, urge, and mixed incontinence. J Wound Ostomy Continence Nurs.
1928 Smith DN, Appell RA, Winters JC, et al. (1997). Collagen injection therapy for female intrinsic sphincteric deficiency. J Urol.
1929 Smith EM, Elder JS. (1994). Double antimicrobial prophylaxis in girls with breakthrough urinary tract infections. Urology.
1930 Smith JC, Dunn M, Ardran GM. (1975). Hydrostatic bladder distension - physiology and clinical application. Eur Urol.
1931 Smith JJ. (1996). Intravaginal stimulation randomized trial. J Urol.
1932 Smith P, Heimer G, Lindskog M, et al. (1993). Oestradiol-releasing vaginal ring for treatment of postmenopausal urogenital atrophy. Maturitas.
1933 Smulders RA, Kuipers ME, Krauwinkel WJ. (2006). Multiple doses of the antimuscarinic agent solifenacin do not affect the pharmacodynamics or pharmacokinetics of warfarin or the steady-state pharmacokinetics of digoxin in healthy subjects. Br J Clin Pharmacol.
1934 Snape J, Castleden CM, Duffin HM, et al. (1989). Long-term follow-up of habit retraining for bladder instability in elderly patients. Age Ageing.
1935 Sobhgol SS, Charandabee SM. (2008). Related factors of urge, stress, mixed urinary incontinence and overactive bladder in reproductive age women in Tabriz, Iran: a cross-sectional study. Int Urogynecol J Pelvic Floor Dysfunct.
1936 Soligo M, Salvatore S, Milani R, et al. (2003). Double incontinence in urogynecologic practice: a new insight. Am J Obstet Gynecol.
1937 Song C, Park SH, Han JY, et al. (2008). Identification of the optimal time to treat urgency after a midurethral sling procedure for stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
1938 Soomro NA, Khadra MH, Robson W, et al. (2001). A crossover randomized trial of transcutaneous electrical nerve stimulation and oxybutynin in patients with detrusor instability. J Urol.
1939 Soontrapa S, Ruksakul W, Nonthasood B, et al. (2003). The efficacy of Thai capsaicin in management of overactive bladder and hypersensitive bladder. J Med Assoc Thai.
1940 Sousa-Escandon A, Lema Grille J, Rodriguez Gomez JI, et al. (2003). Externally readjustable device to regulate sling tension in stress urinary incontinence: preliminary results. J Endourol.
1941 Soygur T, Arikan N, Tokatli Z, et al. (2004). The role of video-urodynamic studies in managing non-neurogenic voiding dysfunction in children. BJU Int.
1942 Soyupek F, Soyupek S, Akkus S, et al. (2007). The coexistence of the fibromyalgia syndrome and the overactive bladder syndrome. Journal of Musculoskeletal Pain.
1943 Sozubir S, Celik A, Emir N, et al. (2005). Consistency of urodynamic parameters in children with detrusor instability: how many times should the bladder be filled?. Urol Int.
1944 Spinelli M, Giardiello G, Gerber M, et al. (2003). New sacral neuromodulation lead for percutaneous implantation using local anesthesia: description and first experience. J Urol.
1945 Spinelli M, Malaguti S, Giardiello G, et al. (2005). A new minimally invasive procedure for pudendal nerve stimulation to treat neurogenic bladder: description of the method and preliminary data. Neurourol Urodyn.
1946 Sprem M, Milicic D, Oreskovic S, et al. (2000). Intravesically administered ketoprofen in treatment of detrusor instability: cross-over study. Croat Med J.
1947 Spruijt J, Vierhout M, Verstraeten R, et al. (2003). Vaginal electrical stimulation of the pelvic floor: a randomized feasibility study in urinary incontinent elderly women. Acta Obstet Gynecol Scand.
1948 Stach-Lempinen B, Hakala AL, Laippala P, et al. (2003). Severe depression determines quality of life in urinary incontinent women. Neurourol Urodyn.
1949 Stage P, Fischer-Rasmussen W, Hansen RI. (1986). The value of colpo-cysto-urethrography in female stress- and urge incontinence and following operation. Acta Obstet Gynecol Scand.
1950 Stanton SL. (1985). Stress incontinence: why and how operations work. Clin Obstet Gynaecol.
1951 Stanton SL, Cardozo L, Williams JE, et al. (1978). Clinical and urodynamic features of failed incontinence surgery in the female. Obstet Gynecol.
1952 Stanton SL, Hilton P, Norton C, et al. (1982). Clinical and urodynamic effects of anterior colporrhaphy and vaginal hysterectomy for prolapse with and without incontinence. Br J Obstet Gynaecol.
1953 Stanton SL, Kerr-Wilson R, Harris VG. (1980). The incidence of urological symptoms in normal pregnancy. Br J Obstet Gynaecol.
1954 Stanton SL, Monga AK. (1997). Incontinence in elderly women: is periurethral collagen an advance?. Br J Obstet Gynaecol.
1955 Starer P, Libow LS. (1988). The measurement of residual urine in the evaluation of incontinent nursing home residents. Arch Gerontol Geriatr.
1956 Starkman JS, Duffy JW, Wolter CE, et al. (2008). The evolution of obstruction induced overactive bladder symptoms following urethrolysis for female bladder outlet obstruction. J Urol.
1957 Starkman JS, Duffy JW, Wolter CE, et al. (2008). Refractory overactive bladder after urethrolysis for bladder outlet obstruction: management with sacral neuromodulation. Int Urogynecol J Pelvic Floor Dysfunct.
1958 Starkman JS, Wolter CE, Scarpero HM, et al. (2007). Management of refractory urinary urge incontinence following urogynecological surgery with sacral neuromodulation. Neurourol Urodyn.
1959 Staskin DR, Choe JM, Breslin DS. (1997). The Gore-tex sling procedure for female sphincteric incontinence: indications, technique, and results. World J Urol.
1960 Staskin DR, Te AE. (2006). Short- and long-term efficacy of solifenacin treatment in patients with symptoms of mixed urinary incontinence. BJU Int.
1961 Stav K, Dwyer PL, Rosamilia A, et al. (2008). Urinary symptoms before and after female urethral diverticulectomy--can we predict de novo stress urinary incontinence?. J Urol.
1962 Steel SA, Cox C, Stanton SL. (1986). Long-term follow-up of detrusor instability following the colposuspension operation. Br J Urol.
1963 Steele AC, Walsh P, Bentley M, et al. (2001). A randomized, double-blind placebo-controlled trial of the effects of the 5-hydroxytriptamine(4) agonist cisapride on the female urinary bladder. Am J Obstet Gynecol.
1964 Steers W. (2000). Pathogenesis of the overactive bladder and its attendant risk factors. BJU Int.
1965 Steers WD, Meythaler JM, Haworth C, et al. (1992). Effects of acute bolus and chronic continuous intrathecal baclofen on genitourinary dysfunction due to spinal cord pathology. J Urol.
1966 Stein M, Discippio W, Davia M, et al. (1995). Biofeedback for the treatment of stress and urge incontinence. J Urol.
1967 Stein RJ, Santos S, Nagatomi J, et al. (2004). Cool (TRPM8) and hot (TRPV1) receptors in the bladder and male genital tract. J Urol.
1968 Steinauer JE, Waetjen LE, Vittinghoff E, et al. (2005). Postmenopausal hormone therapy: does it cause incontinence?. Obstet Gynecol.
1969 Stenberg A, Heimer G, Ulmsten U, et al. (1996). Prevalence of genitourinary and other climacteric symptoms in 61-year-old women. Maturitas.
1970 Stevens LA, Chapple CR, Chess-Williams R. (2007). Human idiopathic and neurogenic overactive bladders and the role of M2 muscarinic receptors in contraction. Eur Urol.
1971 Stewart DJ, Green R, Futter N, et al. (1990). Phase I and pharmacology study of intravesical mitoxantrone for recurrent superficial bladder tumors. J Urol.
1972 Stimpel H, Aagaard J, Reuther K. (1984). Repeated bladder distension by the Cystomat in the treatment of detrusor instability. Br J Urol.
1973 Stohrer M, Murtz G, Kramer G, et al. (2007). Propiverine compared to oxybutynin in neurogenic detrusor overactivity--results of a randomized, double-blind, multicenter clinical study. Eur Urol.
1974 Stothers L, Goldenberg SL, Leone EF. (1998). Complications of periurethral collagen injection for stress urinary incontinence. J Urol.
1975 Su X, Leon LA, Wu CW, et al. (2008). Modulation of bladder function by prostaglandin EP3 receptors in the central nervous system. Am J Physiol Renal Physiol.
1976 Subak LL, Quesenberry CP, Posner SF, et al. (2002). The effect of behavioral therapy on urinary incontinence: a randomized controlled trial. Obstet Gynecol.
1977 Subak LL, Wing R, West DS, et al. (2009). Weight loss to treat urinary incontinence in overweight and obese women. N Engl J Med.
1978 Suchowersky O, Furtado S, Rohs G. (1995). Beneficial effect of intranasal desmopressin for nocturnal polyuria in Parkinson’s disease. Mov Disord.
1979 Sugaya K, Nishijima S, Oda M, et al. (2007). Change of blood viscosity and urinary frequency by high water intake. Int J Urol.
1980 Sugaya K, Nishijima S, Oda M, et al. (2008). Biochemical and body composition analysis of nocturia in the elderly. Neurourol Urodyn.
1981 Sugaya K, Nishizawa O, Satoh T, et al. (2000). Bladder-pumping therapy for the treatment of low-capacity or low-compliance bladders. Neurourol Urodyn.
1982 Sugaya K, Onaga T, Nishijima S, et al. (2007). Relationship between serum cholinesterase level and urinary bladder activity in patients with or without overactive bladder and/or neurogenic bladder. Biomedical Research.
1983 Sugaya K, Onaga T, Nishijima S, et al. (2008). Relationship between serum cholinesterase level and urinary bladder activity in patients with or without overactive bladder and/or neurogenic bladder. Biomed Res.
1984 Suhel P, Kralj B, Plevnik S. (1978). Advances in nonimplantable electrical stimualtors for correction of urinary incontinence. TIT J Life Sci.
1985 Sui GP, Wu C, Severs N, et al. (2007). The association between T-type Ca2+ current and outward current in isolated human detrusor cells from stable and overactive bladders. BJU Int.
1986 Summitt RL, Stovall TG, Bent AE, et al. (1992). Urinary incontinence: correlation of history and brief office evaluation with multichannel urodynamic testing. Am J Obstet Gynecol.
1987 Susset J, Galea G, Manbeck K, et al. (1995). A predictive score index for the outcome of associated biofeedback and vaginal electrical stimulation in the treatment of female incontinence. J Urol.
1988 Sussman DO, Kraus SR, Carlsson M, et al. (2007). Onset of efficacy of tolterodine extended release in patients with overactive bladder. Curr Med Res Opin.
1989 Sutherst JR, Brown MC. (1984). Comparison of single and multichannel cystometry in diagnosing bladder instability. Br Med J (Clin Res Ed).
1990 Sutherst JR, Brown MC, Richmond D. (1986). Analysis of the pattern of urine loss in women with incontinence as measured by weighing perineal pads. Br J Urol.
1991 Suzuki S, Dennerstein L, Greenwood KM, et al. (1994). Sleeping patterns during pregnancy in Japanese women. J Psychosom Obstet Gynaecol.
1992 Svigos JM, Matthews CD. (1977). Assessment and treatment of female urinary incontinence by cystometrogram and bladder retraining programs. Obstet Gynecol.
1993 Svihra J, Kurca E, Luptak J, et al. (2002). Neuromodulative treatment of overactive bladder--noninvasive tibial nerve stimulation. Bratisl Lek Listy.
1994 Swann J. (2005). Simple steps for promoting urinary continence. Nursing & Residential Care.
1995 Swanson SG, Drosman S, Helmond FA, et al. (2006). Tibolone for the treatment of moderate to severe vasomotor symptoms and genital atrophy in postmenopausal women: a multicenter, randomized, double-blind, placebo-controlled study. Menopause.
1996 Swart PJ, Krauwinkel WJ, Smulders RA, et al. (2006). Pharmacokinetic effect of ketoconazole on solifenacin in healthy volunteers. Basic Clin Pharmacol Toxicol.
1997 Sweat SD, Itano NB, Clemens JQ, et al. (2002). Polypropylene mesh tape for stress urinary incontinence: complications of urethral erosion and outlet obstruction. J Urol.
1998 Swierzewski SJ, McGuire EJ. (1993). Pubovaginal sling for treatment of female stress urinary incontinence complicated by urethral diverticulum. J Urol.
1999 Swift SE. (1997). The reliability of performing a screening cystometrogram using a fetal monitoring device for the detection of detrusor instability. Obstet Gynecol.
2000 Swift SE, Yoon EA. (1999). Test-retest reliability of the cough stress test in the evaluation of urinary incontinence. Obstet Gynecol.
2001 Swithinbank LV, James M, Shepherd A, et al. (1999). Role of ambulatory urodynamic monitoring in clinical urological practice. Neurourol Urodyn.
2002 Switzer D, Hendriks O. (1988). Interferential therapy for the treatment of stress and urge incontinence. Ir Med J.
2003 Syrjala KL, Langer SL, Abrams JR, et al. (2005). Late effects of hematopoietic cell transplantation among 10-year adult survivors compared with case-matched controls. J Clin Oncol.
2004 Sze EH, Jones WP, Ferguson JL, et al. (2002). Prevalence of urinary incontinence symptoms among black, white, and Hispanic women. Obstet Gynecol.
2005 Sze EH, Miklos JR, Partoll L, et al. (1997). Sacrospinous ligament fixation with transvaginal needle suspension for advanced pelvic organ prolapse and stress incontinence. Obstet Gynecol.
2006 Tadic SD, Griffiths D, Schaefer W, et al. (2008). Abnormal connections in the supraspinal bladder control network in women with urge urinary incontinence. Neuroimage.
2007 Taekema-Roelvink ME, Swart PJ, Kuipers ME, et al. (2005). Pharmacokinetic interaction of solifenacin with an oral contraceptive containing ethinyl estradiol and levonorgestrel in healthy women: a double-blind, placebo-controlled study. Clin Ther.
2008 Tahseen S, Reid PC, Charan P. (2007). Short-term complications of the trans-obturator foramen procedure for urinary stress incontinence. J Obstet Gynaecol.
2009 Tai HL, Chang YJ, Chang SC, et al. (2007). The epidemiology and factors associated with nocturnal enuresis and its severity in primary school children in Taiwan. Acta Paediatr.
2010 Takahashi R, Nishimura J, Hirano K, et al. (2004). Ca2+ sensitization in contraction of human bladder smooth muscle. J Urol.
2011 Takazawa K, Arisawa K. (2005). Relationship between the type of urinary incontinence and falls among frail elderly women in Japan. J Med Invest.
2012 Takei M, Homma Y. (2005). Long-term safety, tolerability and efficacy of extended-release tolterodine in the treatment of overactive bladder in Japanese patients. Int J Urol.
2013 Tan TL, Bergmann MA, Griffiths D, et al. (2003). Which stop test is best? Measuring detrusor contractility in older females. J Urol.
2014 Tan TL, Bergmann MA, Griffiths D, et al. (2004). Stop test or pressure-flow study? Measuring detrusor contractility in older females. Neurourol Urodyn.
2015 Tanagho EA. (1979). Urodynamics of female urinary incontinence with emphasis on stress incontinence. J Urol.
2016 Tanaka H, Matsuda M, Moriya K, et al. (2008). Ultrasonographic measurement of bladder wall thickness as a risk factor for upper urinary tract deterioration in children with myelodysplasia. J Urol.
2017 Tanaka ST, Stone AR, Kurzrock EA. (2006). Transverse myelitis in children: long-term urological outcomes. J Urol.
2018 Tannenbaum C, Bachand G, Dubeau CE, et al. (2001). Experience of an incontinence clinic for older women: no apparent age limit for potential physical and psychological benefits. J Womens Health Gend Based Med.
2019 Tantanasis T, Giannoulis C, Daniilidis A, et al. (2008). Anterior vaginal wall reconstruction: anterior colporrhaphy reinforced with tension free vaginal tape underneath bladder base. Acta Obstet Gynecol Scand.
2020 Tapp A, Fall M, Norgaard J, et al. (1989). Terodiline: a dose titrated, multicenter study of the treatment of idiopathic detrusor instability in women. J Urol.
2021 Tapp AJ, Cardozo LD, Versi E, et al. (1990). The treatment of detrusor instability in post-menopausal women with oxybutynin chloride: a double blind placebo controlled study. Br J Obstet Gynaecol.
2022 Tarhan F, Erbay E, Eryildirim B, et al. (2004). The effect of intravesical sodium nitroprusside on idiopathic detrusor overactivity. Urol Res.
2023 Taskinen S, Fagerholm R, Rintala R. (2007). Mini-invasive collagen sling in the treatment of urinary incontinence due to sphincteric incompetence. Int Braz J Urol.
2024 Taskinen S, Valanne L, Rintala R. (2002). Effect of spinal cord abnormalities on the function of the lower urinary tract in patients with anorectal abnormalities. J Urol.
2025 Taylor CM, Corkery JJ, White RH. (1982). Micturition symptoms and unstable bladder activity in girls with primary vesicoureteric reflux. Br J Urol.
2026 Taylor PH, Sussman DO. (2005). Contemporary treatment options for overactive bladder. JAAPA.
2027 Taylor T, Smith AN, Fulton M. (1990). Effects of hysterectomy on bowel and bladder function. Int J Colorectal Dis.
2028 Tebyani N, Patel H, Yamaguchi R, et al. (2000). Percutaneous needle bladder neck suspension for the treatment of stress urinary incontinence in women: long-term results. J Urol.
2029 Tegerstedt G, Maehle-Schmidt M, Nyren O, et al. (2005). Prevalence of symptomatic pelvic organ prolapse in a Swedish population. Int Urogynecol J Pelvic Floor Dysfunct.
2030 Tegerstedt G, Sjoberg B, Hammarstrom M. (2001). Clinical outcome or abdominal urethropexy-colposuspension: a long-term follow-up. Int Urogynecol J Pelvic Floor Dysfunct.
2031 Teichman JM, Nielsen-Omeis BJ. (1999). Potassium leak test predicts outcome in interstitial cystitis. J Urol.
2032 Teleman P, Gunnarsson M, Lidfeldt J, et al. (2002). Urodynamic characterisation of women with naive urinary incontinence: a population-based study in subjectively incontinent and healthy 53–63 years old women. Eur Urol.
2033 Teleman P, Lidfeldt J, Nerbrand C, et al. (2005). Lower urinary tract symptoms in middle-aged women--prevalence and attitude towards mild urinary incontinence: a community-based population study. Acta Obstet Gynecol Scand.
2034 Teleman PM, Lidfeldt J, Nerbrand C, et al. (2004). Overactive bladder: prevalence, risk factors and relation to stress incontinence in middle-aged women. BJOG.
2035 Temml C, Heidler S, Ponholzer A, et al. (2005). Prevalence of the overactive bladder syndrome by applying the International Continence Society definition. Eur Urol.
2036 Tennstedt SL, Fitzgerald MP, Nager CW, et al. (2007). Quality of life in women with stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
2037 Teo JS, Briffa NK, Devine A, et al. (2006). Do sleep problems or urinary incontinence predict falls in elderly women?. Aust J Physiother.
2038 Teo RE, Yisa S, Mayne C, et al. (2005). A comparison of urodynamic diagnoses and detrusor muscle function in white and South Indian Asian women. J Urol.
2039 ter Meulen PH, Heesakkers JP, Janknegt RA. (1997). A study on the feasibility of vesicomyotomy in patients with motor urge incontinence. Eur Urol.
2040 Thakar R, Ayers S, Clarkson P, et al. (2002). Outcomes after total versus subtotal abdominal hysterectomy. N Engl J Med.
2041 Thase ME, Shelton RC, Khan A. (2006). Treatment with venlafaxine extended release after SSRI nonresponse or intolerance: a randomized comparison of standard- and higher-dosing strategies. J Clin Psychopharmacol.
2042 Theodorou C, Floratos D, Katsifotis C, et al. (1998). Transvaginal incisionless bladder neck suspension. A simplified technique for female genuine stress incontinence. Int Urol Nephrol.
2043 Theodorou C, Katsifotis C, Bocos J, et al. (2003). Urodynamics prior to renal transplantation--its impact on treatment decision and final results. Scand J Urol Nephrol.
2044 Theofrastous JP, Wyman JF, Bump RC, et al. (2002). Effects of pelvic floor muscle training on strength and predictors of response in the treatment of urinary incontinence. Neurourol Urodyn.
2045 Theofrastous JP, Wyman JF, Bump RC, et al. (1997). Relationship between urethral and vaginal pressures during pelvic muscle contraction. The Continence Program for Women Research Group. Neurourol Urodyn.
2046 Theoharides TC, Sant GR, el-Mansoury M, et al. (1995). Activation of bladder mast cells in interstitial cystitis: a light and electron microscopic study. J Urol.
2047 Thiede HA, Thiede FK. (1990). A glance at the urodynamic database. J Reprod Med.
2048 Thompson JA, O’Sullivan PB, Briffa NK, et al. (2007). Comparison of transperineal and transabdominal ultrasound in the assessment of voluntary pelvic floor muscle contractions and functional manoeuvres in continent and incontinent women. Int Urogynecol J Pelvic Floor Dysfunct.
2049 Thyssen H, Sander P, Lose G. (1999). A vaginal device (continence guard) in the management of urge incontinence in women. Int Urogynecol J Pelvic Floor Dysfunct.
2050 Tibaek S, Gard G, Jensen R. (2005). Pelvic floor muscle training is effective in women with urinary incontinence after stroke: a randomised, controlled and blinded study. Neurourol Urodyn.
2051 Tincello DG, Adams EJ, Sutherst JR, et al. (2000). Oxybutynin for detrusor instability with adjuvant salivary stimulant pastilles to improve compliance: results of a multicentre, randomized controlled trial. BJU Int.
2052 Tincello DG, Richmond DH. (1998). The Larsson frequency/volume chart is not a substitute for cystometry in the investigation of women with urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
2053 Toaff R, Toaff ME. (1974). Diagnosis of impending late abortion. Obstet Gynecol.
2054 Tomoe H, Kondo A, Takei M, et al. (2005). Quality of life assessments in women operated on by tension-free vaginal tape (TVT). Int Urogynecol J Pelvic Floor Dysfunct.
2055 Tomoe H, Sekiguchi Y, Horiguchi M, et al. (2005). Questionnaire survey on female urinary frequency and incontinence. Int J Urol.
2056 Torring J, Petersen T, Klemar B, et al. (1988). Selective sacral rootlet neurectomy in the treatment of detrusor hyperreflexia. Technique and long-term results. J Neurosurg.
2057 Touloupidis S, Papatsoris AG, Thanopoulos C, et al. (2007). Tension-free vaginal tape for the treatment of stress urinary incontinence in geriatric patients. Gerontology.
2058 Tow AM, Toh KL, Chan SP, et al. (2007). Botulinum toxin type A for refractory neurogenic detrusor overactivity in spinal cord injured patients in Singapore. Ann Acad Med Singapore.
2059 Triantafyllidis A, Charalambous S, Papatsoris AG, et al. (2005). Management of nocturnal enuresis in Greek children. Pediatr Nephrol.
2060 Trienekens TA, Stobberingh EE, Winkens RA, et al. (1989). Different lengths of treatment with co-trimoxazole for acute uncomplicated urinary tract infections in women. BMJ.
2061 Trifillis AL, Cui X, Jacobs S, et al. (1995). Culture of bladder epithelium from cystoscopic biopsies of patients with interstitial cystitis. J Urol.
2062 Trockman BA, Leach GE, Hamilton J, et al. (1995). Modified Pereyra bladder neck suspension: 10-year mean followup using outcomes analysis in 125 patients. J Urol.
2063 Trsinar B, Kraij B. (1996). Maximal electrical stimulation in children with unstable bladder and nocturnal enuresis and/or daytime incontinence: a controlled study. Neurourol Urodyn.
2064 Truss MC, Stief CG, Uckert S, et al. (2000). Initial clinical experience with the selective phosphodiesterase-I isoenzyme inhibitor vinpocetine in the treatment of urge incontinence and low compliance bladder. World J Urol.
2065 Tse V, Wills E, Szonyi G, et al. (2000). The application of ultrastructural studies in the diagnosis of bladder dysfunction in a clinical setting. J Urol.
2066 Tseng LH, Liang CC, Lo HP, et al. (2006). The prevalence of urinary incontinence and associated risk factors in Taiwanese women with lower urinary tract symptoms. Chang Gung Med J.
2067 Tsivian A, Kessler O, Mogutin B, et al. (2004). Tape related complications of the tension-free vaginal tape procedure. J Urol.
2068 Tsui KP, Ng SC, Yeh GP, et al. (2008). Outcomes of autologous fascial slingplasty procedure for treating female urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
2069 Tsuzuki T, Epstein JI. (2005). Fibroepithelial polyp of the lower urinary tract in adults. Am J Surg Pathol.
2070 Tyagi S, Tyagi P, Van-le S, et al. (2006). Qualitative and quantitative expression profile of muscarinic receptors in human urothelium and detrusor. J Urol.
2071 Uchiyama T, Sakakibara R, Hattori T, et al. (2003). Short-term effect of a single levodopa dose on micturition disturbance in Parkinson’s disease patients with the wearing-off phenomenon. Mov Disord.
2072 Ueda T, Tamaki M, Ogawa O, et al. (2000). Improvement of interstitial cystitis symptoms and problems that developed during treatment with oral IPD-1151T. J Urol.
2073 Ueda T, Tamaki M, Ogawa O, et al. (2002). Over expression of platelet-derived endothelial cell growth factor/thymidine phosphorylase in patients with interstitial cystitis and bladder carcinoma. J Urol.
2074 Uekado Y, Hirano A, Shinka T, et al. (1994). The effects of intravesical chemoimmunotherapy with epirubicin and bacillus Calmette-Guerin for prophylaxis of recurrence of superficial bladder cancer: a preliminary report. Cancer Chemother Pharmacol.
2075 Uemura S, Homma Y. (2004). Reliability and validity of King’s Health Questionnaire in patients with symptoms of overactive bladder with urge incontinence in Japan. Neurourol Urodyn.
2076 Ukkonen M, Elovaara I, Dastidar P, et al. (2004). Urodynamic findings in primary progressive multiple sclerosis are associated with increased volumes of plaques and atrophy in the central nervous system. Acta Neurol Scand.
2077 Ulmsten U, Andersson KE, Persson CG. (1977). Diagnostic and therapeutic aspects of urge urinary incontinence in women. Urol Int.
2078 Ulmsten U, Ekman G, Andersson KE. (1985). The effect of terodiline treatment in women with motor urge incontinence. Results from a double-blind study and long-term treatment. Am J Obstet Gynecol.
2079 Ulmsten U, Henriksson L, Iosif S. (1982). The unstable female urethra. Am J Obstet Gynecol.
2080 Ulmsten U, Petros P. (1995). Intravaginal slingplasty (IVS): an ambulatory surgical procedure for treatment of female urinary incontinence. Scand J Urol Nephrol.
2081 Ulshofer B, Bihr AM, Bodeker RH, et al. (2001). Randomised, double-blind, placebo-controlled study on the efficacy and tolerance of trospium chloride in patients with motor urge incontinence. Clinical Drug Investigation.
2082 Uluocak N, Oktar T, Acar O, et al. (2008). Positional changes in voiding dynamics of children with non-neurogenic bladder dysfunction. Urology.
2083 Unsal A, Saglam R, Cimentepe E. (2003). Extracorporeal magnetic stimulation for the treatment of stress and urge incontinence in women--results of 1-year follow-up. Scand J Urol Nephrol.
2084 Urwitz-Lane R, Ozel B. (2006). Sexual function in women with urodynamic stress incontinence, detrusor overactivity, and mixed urinary incontinence. Am J Obstet Gynecol.
2085 Ushiroyama T, Ikeda A, Ueki M. (2000). Clinical efficacy of clenbuterol and propiverine in menopausal women with urinary incontinence: improvement in quality of life. J Med.
2086 Vahtera T, Haaranen M, Viramo-Koskela AL, et al. (1997). Pelvic floor rehabilitation is effective in patients with multiple sclerosis. Clin Rehabil.
2087 Valaitis SR, Stanton SL. (1994). Sacrocolpopexy: a retrospective study of a clinician’s experience. Br J Obstet Gynaecol.
2088 Valencic M, Spanjol J, Maricic A, et al. (2008). Cystocoele and sensory urgency--our experience. Coll Antropol.
2089 Van Arendonk KJ, Austin JC, Boyt MA, et al. (2006). Frequency of wetting is predictive of response to anticholinergic treatment in children with overactive bladder. Urology.
2090 van Balen FA, Touw-Otten FW, de Melker RA. (1990). Single-dose pefloxacin versus five-days treatment with norfloxacin in uncomplicated cystitis in women. J Antimicrob Chemother.
2091 van Balken MR, Vandoninck V, Gisolf KW, et al. (2001). Posterior tibial nerve stimulation as neuromodulative treatment of lower urinary tract dysfunction. J Urol.
2092 van Balken MR, Vandoninck V, Messelink BJ, et al. (2003). Percutaneous tibial nerve stimulation as neuromodulative treatment of chronic pelvic pain. Eur Urol.
2093 van Balken MR, Vergunst H, Bemelmans BL. (2006). Prognostic factors for successful percutaneous tibial nerve stimulation. Eur Urol.
2094 van Balken MR, Vergunst H, Bemelmans BL. (2006). Sexual functioning in patients with lower urinary tract dysfunction improves after percutaneous tibial nerve stimulation. Int J Impot Res.
2095 van Brummen HJ, Bruinse HW, van de Pol G, et al. (2006). Bothersome lower urinary tract symptoms 1 year after first delivery: prevalence and the effect of childbirth. BJU Int.
2096 Van Brummen HJ, Bruinse HW, Van de Pol G, et al. (2006). What is the effect of overactive bladder symptoms on woman’s quality of life during and after first pregnancy?. BJU Int.
2097 van Brummen HJ, Bruinse HW, van de Pol G, et al. (2007). The effect of vaginal and cesarean delivery on lower urinary tract symptoms: what makes the difference?. Int Urogynecol J Pelvic Floor Dysfunct.
2098 van Brummen HJ, Bruinse HW, van der Bom JG, et al. (2006). How do the prevalences of urogenital symptoms change during pregnancy?. Neurourol Urodyn.
2099 van Brummen HJ, Heintz AP, van der Vaart CH. (2004). The association between overactive bladder symptoms and objective parameters from bladder diary and filling cystometry. Neurourol Urodyn.
2100 van Brummen HJ, van de Pol G, Aalders CI, et al. (2003). Sacrospinous hysteropexy compared to vaginal hysterectomy as primary surgical treatment for a descensus uteri: effects on urinary symptoms. Int Urogynecol J Pelvic Floor Dysfunct.
2101 van der Pal F, van Balken MR, Heesakkers JP, et al. (2006). Percutaneous tibial nerve stimulation in the treatment of refractory overactive bladder syndrome: is maintenance treatment necessary?. BJU Int.
2102 van der Pal F, van Balken MR, Heesakkers JP, et al. (2006). Correlation between quality of life and voiding variables in patients treated with percutaneous tibial nerve stimulation. BJU Int.
2103 van der Vaart CH, de Leeuw JR, Roovers JP, et al. (2003). Measuring health-related quality of life in women with urogenital dysfunction: the urogenital distress inventory and incontinence impact questionnaire revisited. Neurourol Urodyn.
2104 van der Vaart CH, van der Bom JG, de Leeuw JR, et al. (2002). The contribution of hysterectomy to the occurrence of urge and stress urinary incontinence symptoms. BJOG.
2105 van Gool JD, de Jonge GA. (1989). Urge syndrome and urge incontinence. Arch Dis Child.
2106 Van Kampen M, Bogaert G, Akinwuntan EA, et al. (2004). Long-term efficacy and predictive factors of full spectrum therapy for nocturnal enuresis. J Urol.
2107 van Kerrebroeck P, Abrams P, Lange R, et al. (2004). Duloxetine versus placebo in the treatment of European and Canadian women with stress urinary incontinence. BJOG.
2108 Van Kerrebroeck PE, Amarenco G, Thuroff JW, et al. (1998). Dose-ranging study of tolterodine in patients with detrusor hyperreflexia. Neurourol Urodyn.
2109 Van Laecke E, Wille S, Vande Walle J, et al. (2006). The daytime alarm: a useful device for the treatment of children with daytime incontinence. J Urol.
2110 van Meel TD, de Wachter S, Wyndaele JJ. (2007). Repeated ice water tests and electrical perception threshold determination to detect a neurologic cause of detrusor overactivity. Urology.
2111 van Melick HH, Gisolf KW, Eckhardt MD, et al. (2001). One 24-hour frequency-volume chart in a woman with objective urinary motor urge incontinence is sufficient. Urology.
2112 Van Pienbroek E, Hermans J, Kaptein AA, et al. (1993). Fosfomycin trometamol in a single dose versus seven days nitrofurantoin in the treatment of acute uncomplicated urinary tract infections in women. Pharm World Sci.
2113 van Venrooij GE, Boon TA. (1994). Extensive urodynamic investigation: interaction among diuresis, detrusor instability, urethral relaxation, incontinence and complaints in women with a history of urge incontinence. J Urol.
2114 Van Voskuilen AC, Oerlemans DJ, Weil EH, et al. (2007). Medium-term experience of sacral neuromodulation by tined lead implantation. BJU Int.
2115 van Waalwijk van Doorn ES, Ambergen AW. (1999). Diagnostic assessment of the overactive bladder during the filling phase: the detrusor activity index. BJU Int.
2116 van Waalwijk van Doorn ES, Ambergen AW, Janknegt RA. (1997). Detrusor activity index: quantification of detrusor overactivity by ambulatory monitoring. J Urol.
2117 van Waalwijk van Doorn ES, Remmers A, Janknegt RA. (1991). Extramural ambulatory urodynamic monitoring during natural filling and normal daily activities: evaluation of 100 patients. J Urol.
2118 van Waalwijk van Doorn ES, Remmers A, Janknegt RA. (1992). Conventional and extramural ambulatory urodynamic testing of the lower urinary tract in female volunteers. J Urol.
2119 Vandoninck V, Van Balken MR, Finazzi Agro E, et al. (2003). Posterior tibial nerve stimulation in the treatment of urge incontinence. Neurourol Urodyn.
2120 Vandoninck V, van Balken MR, Finazzi Agro E, et al. (2003). Percutaneous tibial nerve stimulation in the treatment of overactive bladder: urodynamic data. Neurourol Urodyn.
2121 Vardan S, Smulyan H, Mookherjee S, et al. (1983). Effects of tiodazosin, a new antihypertensive, hemodynamics and clinical variables. Clin Pharmacol Ther.
2122 Vasavada SP, Comiter CV, Raz S. (2004). Incisionless pubovaginal fascial sling using transvaginal bone anchors for the treatment of stress urinary incontinence. ScientificWorldJournal.
2123 Vasavada SP, Rackley RR, Appell RA. (1998). In situ anterior vaginal wall sling formation with preservation of the endopelvic fascia for treatment of stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
2124 Velez JB. (1999). Behavior therapy for urge incontinence in older women. J Fam Pract.
2125 Vella M, Robinson D, Cardozo L, et al. (2008). Predicting detrusor overactivity using a physician-based scoring system. Int Urogynecol J Pelvic Floor Dysfunct.
2126 Venn S, Mundy T. (2002). Bladder reconstruction: urothelial augmentation, trauma, fistula. Curr Opin Urol.
2127 Venn SN, Mundy AR. (1998). Long-term results of augmentation cystoplasty. Eur Urol.
2128 Vereecken RL. (2000). The after-contraction: a true detrusor contraction or a late dyssynergic urethral sphincter contraction?. BJU Int.
2129 Vereecken RL, Das J. (1985). Urethral instability: related to stress and/or urge incontinence?. J Urol.
2130 Vereecken RL, Grisar P. (1986). Perineal electromyographic patterns in urge incontinence. Arch Gynecol.
2131 Vereecken RL, Proesmans W. (2000). Extensive surgery on the trigone for complete ureteral duplication does not cause incontinence or voiding problems. Urology.
2132 Vereecken RL, Proesmans W. (2000). Urethral instability as an important element of dysfunctional voiding. J Urol.
2133 Versi E, Griffiths DJ, Harvey MA. (1998). A new external urethral occlusive device for female urinary incontinence. Obstet Gynecol.
2134 Versi E, Orrego G, Hardy E, et al. (1996). Evaluation of the home pad test in the investigation of female urinary incontinence. Br J Obstet Gynaecol.
2135 Vervest HA, Kiewiet de Jonge M, Vervest TM, et al. (1988). Micturition symptoms and urinary incontinence after non-radical hysterectomy. Acta Obstet Gynecol Scand.
2136 Vervest HA, van Venrooij GE, Barents JW, et al. (1989). Non-radical hysterectomy and the function of the lower urinary tract. I: Urodynamic quantification of changes in storage function. Acta Obstet Gynecol Scand.
2137 Videla FL, Wall LL. (1998). Stress incontinence diagnosed without multichannel urodynamic studies. Obstet Gynecol.
2138 Viereck V, Bader W, Krauss T, et al. (2005). Intra-operative introital ultrasound in Burch colposuspension reduces post-operative complications. BJOG.
2139 Viereck V, Bader W, Skala C, et al. (2004). Determination of bladder neck position by intraoperative introital ultrasound in colposuspension: outcome at 6-month follow-up. Ultrasound Obstet Gynecol.
2140 Viereck V, Pauer HU, Bader W, et al. (2004). Introital ultrasound of the lower genital tract before and after colposuspension: a 4-year objective follow-up. Ultrasound Obstet Gynecol.
2141 Viereck V, Pauer HU, Hesse O, et al. (2006). Urethral hypermobility after anti-incontinence surgery - a prognostic indicator?. Int Urogynecol J Pelvic Floor Dysfunct.
2142 Vierhout ME, Mulder AF. (1992). De novo detrusor instability after Burch colposuspension. Acta Obstet Gynecol Scand.
2143 Vijverberg MA, Elzinga-Plomp A, Messer AP, et al. (1997). Bladder rehabilitation, the effect of a cognitive training programme on urge incontinence. Eur Urol.
2144 Viktrup L. (2002). The risk of lower urinary tract symptoms five years after the first delivery. Neurourol Urodyn.
2145 Viktrup L, Lose G. (2000). Lower urinary tract symptoms 5 years after the first delivery. Int Urogynecol J Pelvic Floor Dysfunct.
2146 Vine MF, Calingaert B, Berchuck A, et al. (2003). Characterization of prediagnostic symptoms among primary epithelial ovarian cancer cases and controls. Gynecol Oncol.
2147 Vinson RK, Diokno AC. (1976). Uninhibited neurogenic bladder in adults. Urology.
2148 Virtanen H, Makinen J, Tenho T, et al. (1993). Effects of abdominal hysterectomy on urinary and sexual symptoms. Br J Urol.
2149 Visco AG, Weidner AC, Cundiff GW, et al. (1999). Observed patient compliance with a structured outpatient bladder retraining program. Am J Obstet Gynecol.
2150 Viseshsindh W, Kochakarn W, Waikakul W, et al. (2003). A randomized controlled trial of pubovaginal sling versus vaginal wall sling for stress urinary incontinence. J Med Assoc Thai.
2151 von Gontard A, Lettgen B, Olbing H, et al. (1998). Behavioural problems in children with urge incontinence and voiding postponement: a comparison of a paediatric and child psychiatric sample. Br J Urol.
2152 von Gontard A, Mauer-Mucke K, Pluck J, et al. (1999). Clinical behavioral problems in day- and night-wetting children. Pediatr Nephrol.
2153 Voorham-van der Zalm PJ, Pelger RC, Stiggelbout AM, et al. (2006). Effects of magnetic stimulation in the treatment of pelvic floor dysfunction. BJU Int.
2154 Wada Y, Ando Y, Kai N, et al. (2006). Lower urinary tract dysfunction in type 1 familial amyloidotic polyneuropathy in Kumamoto, Japan. Int J Urol.
2155 Wadie BS. (2004). Primary nocturnal enuresis persistent to adulthood, functional evaluation. Neurourol Urodyn.
2156 Wadie BS, Edwan A, Nabeeh AM. (2005). Autologous fascial sling vs polypropylene tape at short-term followup: a prospective randomized study. J Urol.
2157 Wagener N, Reitz A, Pfitzenmaier J, et al. (2005). Adherens junctions of the human detrusor. BJU Int.
2158 Wagg A, Bayliss M, Ingham NJ, et al. (1998). Urodynamic variables cannot be used to classify the severity of detrusor instability. Br J Urol.
2159 Wagg A, Wyndaele JJ, Sieber P. (2006). Efficacy and tolerability of solifenacin in elderly subjects with overactive bladder syndrome: a pooled analysis. Am J Geriatr Pharmacother.
2160 Wagg AS, Lieu PK, Ding YY, et al. (1996). A urodynamic analysis of age associated changes in urethral function in women with lower urinary tract symptoms. J Urol.
2161 Wagner TH, Hu TW. (1998). Economic costs of urinary incontinence in 1995. Urology.
2162 Walker J, Rickwood AM. (1988). Daytime urinary frequency in children. BMJ.
2163 Wall LL, Copas P, Galloway NT. (1996). Use of a pedicled rectus abdominis muscle flap sling in the treatment of complicated stress urinary incontinence. Am J Obstet Gynecol.
2164 Wall LL, Hewitt JK. (1994). Urodynamic characteristics of women with complete posthysterectomy vaginal vault prolapse. Urology.
2165 Wall LL, Stanton SL. (1989). Transvesical phenol injection of pelvic nerve plexuses in females with refractory urge incontinence. Br J Urol.
2166 Wall LL, Wiskind AK, Taylor PA. (1994). Simple bladder filling with a cough stress test compared with subtracted cystometry for the diagnosis of urinary incontinence. Am J Obstet Gynecol.
2167 Wallwiener D, Grischke EM, Rimbach S, et al. (1995). Endoscopic retropubic colposuspension: “Retziusscopy” versus laparoscopy--a reasonable enlargement of the operative spectrum in the management of recurrent stress incontinence?. Endosc Surg Allied Technol.
2168 Walsh IK, Nambirajan T, Donellan SM, et al. (2002). Cadaveric fascia lata pubovaginal slings: early results on safety, efficacy and patient satisfaction. BJU Int.
2169 Walter S. (1978). Detrusor hyperreflexia in female urinary incontinence treated pharmacologically. Urol Int.
2170 Walter S, Meyhoff HH, Gerstenberg T, et al. (1984). Urinary incontinence in the female. A long-term study of the effect of anticholinergics on overactive detrusor function. Acta Obstet Gynecol Scand.
2171 Walter S, Olesen KP. (1982). Urinary incontinence and genital prolapse in the female: clinical, urodynamic and radiological examinations. Br J Obstet Gynaecol.
2172 Walter U, Dressler D, Wolters A, et al. (2006). Overactive bladder in Parkinson’s disease: alteration of brainstem raphe detected by transcranial sonography. Eur J Neurol.
2173 Walters MD, Shields LE. (1988). The diagnostic value of history, physical examination, and the Q-tip cotton swab test in women with urinary incontinence. Am J Obstet Gynecol.
2174 Walters MD, Taylor S, Schoenfeld LS. (1990). Psychosexual study of women with detrusor instability. Obstet Gynecol.
2175 Wan EC, Gordon TP, Jackson MW. (2008). Autoantibodies to calcium channels in type 1 diabetes mediate autonomic dysfunction by different mechanisms in colon and bladder and are neutralized by antiidiotypic antibodies. J Autoimmun.
2176 Wang AC. (1996). Burch colposuspension vs. Stamey bladder neck suspension. A comparison of complications with special emphasis on detrusor instability and voiding dysfunction. J Reprod Med.
2177 Wang AC. (2000). Bladder-sphincter biofeedback as treatment of detrusor instability in women who failed to respond to oxybutynin. Chang Gung Med J.
2178 Wang AC, Wu RC, Lin CT, et al. (2008). A microbiological and immunohistochemical analysis of periurethral and vaginal tissue in women with de novo urge symptoms after mid-urethral sling procedures--a prospective case-controlled study. Int Urogynecol J Pelvic Floor Dysfunct.
2179 Wang HZ, Brink PR, Christ GJ. (2006). Gap junction channel activity in short-term cultured human detrusor myocyte cell pairs: gating and unitary conductances. Am J Physiol Cell Physiol.
2180 Wang KH, Neimark M, Davila GW. (2002). Voiding dysfunction following TVT procedure. Int Urogynecol J Pelvic Floor Dysfunct.
2181 Wanigasuriya JK, Wijewickrama ES, Jayasekara WM, et al. (2007). Lower urinary tract symptoms; an undetected cause for morbidity in adults. Ceylon Med J.
2182 Warne SA, Godley ML, Wilcox DT. (2004). Surgical reconstruction of cloacal malformation can alter bladder function: a comparative study with anorectal anomalies. J Urol.
2183 Warren JW. (1994). Is interstitial cystitis an infectious disease?. Med Hypotheses.
2184 Washington BB, Hines BJ. (2007). Implant infection after two-stage sacral nerve stimulator placement. Int Urogynecol J Pelvic Floor Dysfunct.
2185 Watanabe T, Yokoyama T, Sasaki K, et al. (2004). Intravesical resiniferatoxin for patients with neurogenic detrusor overactivity. Int J Urol.
2186 Wattanayingcharoenchai R, Manonai J, Vannatim N, et al. (2007). Impact of stress urinary incontinence and overactive bladder on quality of life in Thai women attending the urogynecology clinic. J Med Assoc Thai.
2187 Webb RJ, Ramsden PD, Neal DE. (1991). Ambulatory monitoring and electronic measurement of urinary leakage in the diagnosis of detrusor instability and incontinence. Br J Urol.
2188 Weber AM, Abrams P, Brubaker L, et al. (2001). The standardization of terminology for researchers in female pelvic floor disorders. Int Urogynecol J Pelvic Floor Dysfunct.
2189 Weber AM, Walters MD. (2000). Burch procedure compared with sling for stress urinary incontinence: a decision analysis. Obstet Gynecol.
2190 Weber AM, Walters MD. (2000). Cost-effectiveness of urodynamic testing before surgery for women with pelvic organ prolapse and stress urinary incontinence. Am J Obstet Gynecol.
2191 Webster DC. (1993). Interstitial cystitis: women at risk for psychiatric misdiagnosis. AWHONNS Clin Issues Perinat Womens Health Nurs.
2192 Webster DC. (1997). Recontextualizing sexuality in chronic illness: women and interstitial cystitis. Health Care Women Int.
2193 Webster DC, Brennan T. (1994). Use and effectiveness of physical self-care strategies for interstitial cystitis. Nurse Pract.
2194 Webster GD, Koefoot RB, Sihelnik S. (1984). Urodynamic abnormalities in neurologically normal children with micturition dysfunction. J Urol.
2195 Weerasekera DS, Gunawardena KK. (1995). The Stamy procedure: a retrospective analysis of clinical outcome in stress incontinence. Ceylon Med J.
2196 Weerasinghe N, Malone PS. (1993). The value of videourodynamics in the investigation of neurologically normal children who wet. Br J Urol.
2197 Weese DL, Roskamp DA, Leach GE, et al. (1993). Intravesical oxybutynin chloride: experience with 42 patients. Urology.
2198 Weidner AC, Myers ER, Visco AG, et al. (2001). Which women with stress incontinence require urodynamic evaluation?. Am J Obstet Gynecol.
2199 Weil A, Miege B, Rottenberg R, et al. (1986). Clinical significance of urethral instability. Obstet Gynecol.
2200 Weil EH, Ruiz-Cerda JL, Eerdmans PH, et al. (2000). Sacral root neuromodulation in the treatment of refractory urinary urge incontinence: a prospective randomized clinical trial. Eur Urol.
2201 Weil EH, Ruiz-Cerda JL, Eerdmans PH, et al. (1998). Clinical results of sacral neuromodulation for chronic voiding dysfunction using unilateral sacral foramen electrodes. World J Urol.
2202 Wein AJ. (2000). Overactive bladder: defining the disease. Am J Manag Care.
2203 Wein AJ. (2005). Urgency: the cornerstone symptom of overactive bladder. J Urol.
2204 Wein AJ, Khullar V, Wang JT, et al. (2007). Achieving continence with antimuscarinic therapy for overactive bladder: effects of baseline incontinence severity and bladder diary duration. BJU Int.
2205 Wein AJ, Rovner ES. (2002). Definition and epidemiology of overactive bladder. Urology.
2206 Weinberger MW, Goodman BM, Carnes M. (1999). Long-term efficacy of nonsurgical urinary incontinence treatment in elderly women. J Gerontol A Biol Sci Med Sci.
2207 Weinberger MW, Ostergard DR. (1995). Long-term clinical and urodynamic evaluation of the polytetrafluoroethylene suburethral sling for treatment of genuine stress incontinence. Obstet Gynecol.
2208 Weiss GR, O’Donnell MA, Loughlin K, et al. (2003). Phase 1 study of the intravesical administration of recombinant human interleukin-12 in patients with recurrent superficial transitional cell carcinoma of the bladder. J Immunother.
2209 Weiss JP, Blaivas JG, Jones M, et al. (2007). Age related pathogenesis of nocturia in patients with overactive bladder. J Urol.
2210 Weiss JP, Blaivas JG, Stember DS, et al. (1998). Nocturia in adults: etiology and classification. Neurourol Urodyn.
2211 Wells TJ, Brink CA, Diokno AC. (1987). Urinary incontinence in elderly women: clinical findings. J Am Geriatr Soc.
2212 Wen JG, Tong EC. (1998). Cystometry in infants and children with no apparent voiding symptoms. Br J Urol.
2213 Wen JG, Yeung CK, Chu WC, et al. (2001). Video cystometry in young infants with renal dilation or a history of urinary tract infection. Urol Res.
2214 Wennberg AL, Edlund C, Fall M, et al. (2003). Stamey’s abdominovaginal needle colposuspension for the correction of female genuine stress urinary incontinence--long-term results. Scand J Urol Nephrol.
2215 Werner M, Schmid DM, Schussler B. (2005). Efficacy of botulinum-A toxin in the treatment of detrusor overactivity incontinence: a prospective nonrandomized study. Am J Obstet Gynecol.
2216 Wester C, FitzGerald MP, Brubaker L, et al. (2003). Validation of the clinical bulbocavernosus reflex. Neurourol Urodyn.
2217 Westney OL, Amundsen CL, McGuire EJ. (2000). Bladder endometriosis: conservative management. J Urol.
2218 Westney OL, Lee JT, McGuire EJ, et al. (2002). Long-term results of Ingelman-Sundberg denervation procedure for urge incontinence refractory to medical therapy. J Urol.
2219 Wheelahan JB. (1986). The pressure-volume plot and prediction of treatment outcome in female incontinence. Br J Urol.
2220 Wheelahan JB. (1990). Long-term results of colposuspension. Br J Urol.
2221 Whelan CM, McKenna PH. (2004). Urologic applications of biofeedback therapy. Contemporary Urology.
2222 White WM, Pickens RB, Doggweiler R, et al. (2008). Short-term efficacy of botulinum toxin a for refractory overactive bladder in the elderly population. J Urol.
2223 Whiteside JL, Hijaz A, Imrey PB, et al. (2006). Reliability and agreement of urodynamics interpretations in a female pelvic medicine center. Obstet Gynecol.
2224 Whitler ET, Feltner F, Owens J, et al. (2005). Kentucky Homeplace Defeat Diabetes Screening Test: an analysis of rural Kentucky’s challenge to overcome the growing diabetes epidemic. J Ky Med Assoc.
2225 Wiener JS, Scales MT, Hampton J, et al. (2000). Long-term efficacy of simple behavioral therapy for daytime wetting in children. J Urol.
2226 Wiener LB, Baum NH, Suarez GM. (1986). New method for management of detrusor instability: transdermal scopolamine. Urology.
2227 Wijma J, Tinga DJ, Visser GH. (1992). Compensatory mechanisms which prevent urinary incontinence in aging women. Gynecol Obstet Invest.
2228 Wilkinson E. (2006). Urinary incontinence in women. Nurs Times.
2229 Wilson S, Quek ML, Ginsberg DA. (2004). Transurethral injection of bulking agents for stress urinary incontinence following orthotopic neobladder reconstruction in women. J Urol.
2230 Winder A. (2005). Antimuscarinic management of overactive bladder. Br J Community Nurs.
2231 Winge K, Friberg L, Werdelin L, et al. (2005). Relationship between nigrostriatal dopaminergic degeneration, urinary symptoms, and bladder control in Parkinson’s disease. Eur J Neurol.
2232 Winge K, Nielsen KK, Stimpel H, et al. (2007). Lower urinary tract symptoms and bladder control in advanced Parkinson’s disease: effects of deep brain stimulation in the subthalamic nucleus. Mov Disord.
2233 Winge K, Skau AM, Stimpel H, et al. (2006). Prevalence of bladder dysfunction in Parkinsons disease. Neurourol Urodyn.
2234 Winiecka W, Zoch-Zwierz W, Wasilewska A, et al. (2002). Evaluation of bladder instability in children with recurrent urinary tract infections. Med Sci Monit.
2235 Winkler HA, Sand PK. (1998). Treatment of detrusor instability with oxybutynin rectal suppositories. Int Urogynecol J Pelvic Floor Dysfunct.
2236 Winters JC, Appell RA. (1996). Collagen injection therapy in the treatment of urinary incontinence. Tech Urol.
2237 Wise BG, Cardozo LD. (1993). Urinary urgency in women. Br J Hosp Med.
2238 Wise BG, Cardozo LD, Cutner A, et al. (1993). Prevalence and significance of urethral instability in women with detrusor instability. Br J Urol.
2239 Wiseman PA, Malone-Lee J, Rai GS. (1991). Terodiline with bladder retraining for treating detrusor instability in elderly people. BMJ.
2240 Wiskind AK, Miller KF, Wall LL. (1994). One hundred unstable bladders. Obstet Gynecol.
2241 Wong T, Lau BY, Mak HL, et al. (2006). Changing prevalence and knowledge of urinary incontinence among Hong Kong Chinese women. Int Urogynecol J Pelvic Floor Dysfunct.
2242 Woodman PJ, Misko CA, Fischer JR. (2001). The use of short-form quality of life questionnaires to measure the impact of imipramine on women with urge incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
2243 Woodtli A. (1995). Stress incontinence: clinical identification and validation of defining characteristics. Nurs Diagn.
2244 Woodtli MA. (1993). Assessing urge incontinence in elderly women. Geriatr Nurs.
2245 Wraige E, Borzyskowski M. (2002). Investigation of daytime wetting: when is spinal cord imaging indicated?. Arch Dis Child.
2246 Wu CC, Huang MY, Kapoor R, et al. (2008). Metabolism of omega-6 polyunsaturated fatty acids in women with dysmenorrhea. Asia Pac J Clin Nutr.
2247 Wu EQ, Birnbaum H, Kang YJ, et al. (2006). A retrospective claims database analysis to assess patterns of interstitial cystitis diagnosis. Curr Med Res Opin.
2248 Wu EQ, Birnbaum H, Marynchenko M, et al. (2005). Employees with overactive bladder: work loss burden. J Occup Environ Med.
2249 Wu JM, Williams KS, Hundley AF, et al. (2006). Microscopic hematuria as a predictive factor for detecting bladder cancer at cystoscopy in women with irritative voiding symptoms. Am J Obstet Gynecol.
2250 Wu WJ, Chen MT, Huang CN, et al. (1993). Experience in the morbidity associated with double-J catheter indwelling and its management. Gaoxiong Yi Xue Ke Xue Za Zhi.
2251 Wujanto R, O’Reilly PH. (1989). Stamey needle suspension for stress urinary incontinence. A prospective study of 40 patients. Br J Urol.
2252 Wyman JF, Choi SC, Harkins SW, et al. (1988). The urinary diary in evaluation of incontinent women: a test-retest analysis. Obstet Gynecol.
2253 Wyman JF, Elswick RK, Ory MG, et al. (1993). Influence of functional, urological, and environmental characteristics on urinary incontinence in community-dwelling older women. Nurs Res.
2254 Wyman JF, Fantl JA. (1991). Bladder training in ambulatory care management of urinary incontinence. Urol Nurs.
2255 Wyman JF, Fantl JA, McClish DK, et al. (1997). Quality of life following bladder training in older women with urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct.
2256 Wyman JF, Harkins SW, Choi SC, et al. (1987). Psychosocial impact of urinary incontinence in women. Obstet Gynecol.
2257 Wyndaele JJ, Van Meel TD, De Wachter S. (2004). Detrusor overactivity. Does it represent a difference if patients feel the involuntary contractions?. J Urol.
2258 Yalcin I, Versi E, Benson JT, et al. (2004). Validation of a clinical algorithm to diagnose stress urinary incontinence for large studies. J Urol.
2259 Yalcin OT, Hassa H, Sarac I. (2002). Short-term intravaginal maximal electrical stimulation for refractive detrusor instability. Int J Gynaecol Obstet.
2260 Yalcin OT, Yildirim A, Hassa H. (2001). The effects of severe cystocele on urogynecologic symptoms and findings. Acta Obstet Gynecol Scand.
2261 Yamada T, Arai G, Masuda H, et al. (1998). The correction of type 2 stress incontinence with a polytetrafluoroethylene patch sling: 5-year mean followup. J Urol.
2262 Yamada T, Nishimura M, Mita H. (2007). Increased number of apoptotic endothelial cells in bladder of interstitial cystitis patients. World J Urol.
2263 Yamaguchi C, Sakakibara R, Uchiyama T, et al. (2006). Bladder sensation in peripheral nerve lesions. Neurourol Urodyn.
2264 Yamamoto T, Sakakibara R, Uchiyama T, et al. (2005). When is Onuf’s nucleus involved in multiple system atrophy? A sphincter electromyography study. J Neurol Neurosurg Psychiatry.
2265 Yamamoto T, Sakakibara R, Uchiyama T, et al. (2006). Neurological diseases that cause detrusor hyperactivity with impaired contractile function. Neurourol Urodyn.
2266 Yamanishi T, Sakakibara R, Uchiyama T, et al. (2000). Comparative study of the effects of magnetic versus electrical stimulation on inhibition of detrusor overactivity. Urology.
2267 Yamanishi T, Yasuda K, Hamano S, et al. (2000). Urethral obstruction in patients with nighttime wetting: urodynamic evaluation and outcome of surgical incision. Neurourol Urodyn.
2268 Yamanishi T, Yasuda K, Murayama N, et al. (2000). Biofeedback training for detrusor overactivity in children. J Urol.
2269 Yamanishi T, Yasuda K, Sakakibara R, et al. (2000). Randomized, double-blind study of electrical stimulation for urinary incontinence due to detrusor overactivity. Urology.
2270 Yamanishi T, Yasuda K, Sakakibara R, et al. (1998). Detrusor overactivity and penile erection in patients with lower lumbar spine lesions. Eur Urol.
2271 Yamanishi T, Yasuda K, Suda S, et al. (2000). Effect of functional continuous magnetic stimulation for urinary incontinence. J Urol.
2272 Yamao Y, Kawauchi A, Tanaka Y, et al. (1999). Systematic treatment for nocturnal urinary frequency following a sleep-micturition chart. Psychiatry Clin Neurosci.
2273 Yamashita H, Kumazawa J. (1991). Voiding dysfunction: patients with human T-lymphotropic-virus-type-1-associated myelopathy. Urol Int.
2274 Yang JM, Huang WC. (2002). Discrimination of bladder disorders in female lower urinary tract symptoms on ultrasonographic cystourethrography. J Ultrasound Med.
2275 Yang JM, Huang WC. (2002). Implications of abdominal straining in women with lower urinary tract symptoms. Urology.
2276 Yang JM, Huang WC. (2003). Bladder wall thickness on ultrasonographic cystourethrography: affecting factors and their implications. J Ultrasound Med.
2277 Yang JM, Yang SH, Huang WC. (2006). A surgical technique to adjust bladder neck suspension in laparoscopic Burch colposuspension. J Minim Invasive Gynecol.
2278 Yantiss RK, Clement PB, Young RH. (2001). Endometriosis of the intestinal tract: a study of 44 cases of a disease that may cause diverse challenges in clinical and pathologic evaluation. Am J Surg Pathol.
2279 Yeung CK, Godley ML, Duffy PG, et al. (1995). Natural filling cystometry in infants and children. Br J Urol.
2280 Yeung CK, Godley ML, Ho CK, et al. (1995). Some new insights into bladder function in infancy. Br J Urol.
2281 Yeung CK, Sihoe JD, Sit FK, et al. (2004). Urodynamic findings in adults with primary nocturnal enuresis. J Urol.
2282 Yeung CK, Sit FK, To LK, et al. (2002). Reduction in nocturnal functional bladder capacity is a common factor in the pathogenesis of refractory nocturnal enuresis. BJU Int.
2283 Yeung CK, Sreedhar B, Leung YF, et al. (2007). Correlation between ultrasonographic bladder measurements and urodynamic findings in children with recurrent urinary tract infection. BJU Int.
2284 Yiangou Y, Facer P, Ford A, et al. (2001). Capsaicin receptor VR1 and ATP-gated ion channel P2X3 in human urinary bladder. BJU Int.
2285 Yip SK, Chan A, Pang S, et al. (2003). The impact of urodynamic stress incontinence and detrusor overactivity on marital relationship and sexual function. Am J Obstet Gynecol.
2286 Yip SK, Pang MW. (2006). Tension-free vaginal tape sling procedure for the treatment of stress urinary incontinence in Hong Kong women with and without pelvic organ prolapse: 1-year outcome study. Hong Kong Med J.
2287 Yip SK, Sahota D, Chang AM, et al. (2002). Four-year follow-up of women who were diagnosed to have postpartum urinary retention. Am J Obstet Gynecol.
2288 Yokoyama T, Fujita O, Nishiguchi J, et al. (2004). Extracorporeal magnetic innervation treatment for urinary incontinence. Int J Urol.
2289 Yokoyama T, Kumon H, Nagai A. (2008). Correlation of urinary nerve growth factor level with pathogenesis of overactive bladder. Neurourol Urodyn.
2290 Yokoyama T, Nozaki K, Fujita O, et al. (2004). Role of C afferent fibers and monitoring of intravesical resiniferatoxin therapy for patients with idiopathic detrusor overactivity. J Urol.
2291 Yono M, Yohida M, Wada Y, et al. (1999). Pharmacological effects of tolterodine on human isolated urinary bladder. Eur J Pharmacol.
2292 Yoon HS, Song HH, Ro YJ. (2003). A comparison of effectiveness of bladder training and pelvic muscle exercise on female urinary incontinence. Int J Nurs Stud.
2293 Yoon SM, Jung JK, Lee SB, et al. (2002). Treatment of female urethral syndrome refractory to antibiotics. Yonsei Med J.
2294 Yoshimura K, Terai A. (2005). Classification and distribution of symptomatic nocturia with special attention to duration of time in bed: a patient-based study. BJU Int.
2295 Yossepowitch O, Gillon G, Baniel J, et al. (2001). The effect of cholinergic enhancement during filling cystometry: can edrophonium chloride be used as a provocative test for overactive bladder?. J Urol.
2296 Young AE, Fine PM, McCrery R, et al. (2007). Spanish language translation of pelvic floor disorders instruments. Int Urogynecol J Pelvic Floor Dysfunct.
2297 Young SB, Howard AE, Baker SP. (2001). Mersilene mesh sling: short- and long-term clinical and urodynamic outcomes. Am J Obstet Gynecol.
2298 Yu HJ, Lee WC, Lee KL, et al. (2004). Voiding dysfunction in women with systemic lupus erythematosus. Arthritis Rheum.
2299 Yu LC, Rohner TJ, Kaltreider DL, et al. (1990). Profile of urinary incontinent elderly in long-term care institutions. J Am Geriatr Soc.
2300 Yu YF, Nichol MB, Yu AP, et al. (2005). Persistence and adherence of medications for chronic overactive bladder/urinary incontinence in the california medicaid program. Value Health.
2301 Yucel S, Akkaya E, Guntekin E, et al. (2005). Can alpha-blocker therapy be an alternative to biofeedback for dysfunctional voiding and urinary retention? A prospective study. J Urol.
2302 Yucel S, Akkaya E, Guntekin E, et al. (2005). Should we switch over to tolterodine in every child with non-neurogenic daytime urinary incontinence in whom oxybutynin failed?. Urology.
2303 Yucel S, Kutlu O, Kukul E, et al. (2004). Impact of urodynamics in treatment of primary nocturnal enuresis persisting into adulthood. Urology.
2304 Zachoval R, Pitha J, Medova E, et al. (2003). Augmentation cystoplasty in patients with multiple sclerosis. Urol Int.
2305 Zahariou A, Karamouti M, Karagiannis G, et al. (2008). Maximal bladder capacity is a positive predictor of response to desmopressin treatment in patients with MS and nocturia. Int Urol Nephrol.
2306 Zajaczkowska M, Moulhee NM, Piechuta L, et al. (2004). Dysfunctional voiding and urodynamic disorders in children with recurrent urinary tract infection. Ann Univ Mariae Curie Sklodowska [Med].
2307 Zanoschi C, Carauleanu A. (2003). The use of the supra-pubic fibrous complex in isthmic hysteropexies. Rev Med Chir Soc Med Nat Iasi.
2308 Zarina B, Juwita S, Nor GRM. (2005). Prevalence and factors associated with urinary incontinence in adult women attending family medicine clinic. International Medical Journal.
2309 Zeidman EJ, Helfrick B, Pollard C, et al. (1994). Bacillus Calmette-Guerin immunotherapy for refractory interstitial cystitis. Urology.
2310 Zeng Y, Wu XX, Homma Y, et al. (2007). Uroplakin III-delta4 messenger RNA as a promising marker to identify nonulcerative interstitial cystitis. J Urol.
2311 Zermann DH, Loffler U, Reichelt O, et al. (2003). Bladder dysfunction and end stage renal disease. Int Urol Nephrol.
2312 Zhang CO, Li ZL, Kong CZ. (2005). APF, HB-EGF, and EGF biomarkers in patients with ulcerative vs. non-ulcerative interstitial cystitis. BMC Urol.
2313 Zhang J, Haselden P, Tepe R. (2006). A case series of reduced urinary incontinence in elderly patients following chiropractic manipulation. Journal of Chiropractic Medicine.
2314 Zhao J, Bai J, Zhou Y, et al. (2008). Posterior tibial nerve stimulation twice a week in patients with interstitial cystitis. Urology.
2315 Zink S, Freitag CM, von Gontard A. (2008). Behavioral comorbidity differs in subtypes of enuresis and urinary incontinence. J Urol.
2316 Zinner N, Harnett M, Sabounjian L, et al. (2005). The overactive bladder-symptom composite score: a composite symptom score of toilet voids, urgency severity and urge urinary incontinence in patients with overactive bladder. J Urol.
2317 Zobrist RH, Quan D, Thomas HM, et al. (2003). Pharmacokinetics and metabolism of transdermal oxybutynin: in vitro and in vivo performance of a novel delivery system. Pharm Res.
2318 Zollner-Nielsen M, Samuelsson SM. (1992). Maximal electrical stimulation of patients with frequency, urgency and urge incontinence. Report of 38 cases. Acta Obstet Gynecol Scand.
2319 Zorn BH, Montgomery H, Pieper K, et al. (1999). Urinary incontinence and depression. J Urol.
2320 Zoubek J, Bloom DA, Sedman AB. (1990). Extraordinary urinary frequency. Pediatrics.
2321 Zoubek J, McGuire EJ, Noll F, et al. (1989). The late occurrence of urinary tract damage in patients successfully treated by radiotherapy for cervical carcinoma. J Urol.
2322 Zozikov B, Kunchev SI, Varlev C. (2001). Application of clenbuterol in the treatment of urinary incontinence. Int Urol Nephrol.
2323 Zullo MA, Plotti F, Calcagno M, et al. (2005). Vaginal estrogen therapy and overactive bladder symptoms in postmenopausal patients after a tension-free vaginal tape procedure: a randomized clinical trial. Menopause.
2324 Zullo MA, Ruggiero A, Plotti F, et al. (2008). Anterior colporrhaphy plus inside-out tension-free vaginal tape for associated stress urinary incontinence and cystocele. J Minim Invasive Gynecol.
2325 Zupi E, Marconi D, Sbracia M, et al. (2005). Directed laparoscopic cryomyolysis for symptomatic leiomyomata: one-year follow up. J Minim Invasive Gynecol.
2326 Zupi E, Piredda A, Marconi D, et al. (2004). Directed laparoscopic cryomyolysis: a possible alternative to myomectomy and/or hysterectomy for symptomatic leiomyomas. Am J Obstet Gynecol.
2327 Zuraw BL, Sugimoto S, Parsons CL, et al. (1994). Activation of urinary kallikrein in patients with interstitial cystitis. J Urol.