# Appendix C Evidence Tables

Evidence Table

Study Description | Study Design, Interventions, and Population | Inclusion/Exclusion Criteria | Symptom Characteristics | Outcomes | Quality Rating
Author: Country and setting: Enrollment period: Funding: Author industry relationship disclosures: | Design: Intervention: Groups: N at enrollment: N at follow-up: Age, yrs ± SD: Race/ethnicity, mean ± SD: Women, N (%): Parity mean ± SD: | Inclusion criteria: Exclusion criteria: | Incontinence: Urgency: Frequency: | Outcomes: Modifiers

Evidence Table 1 KQ 1 Prevalence and Incidence of OAB

Study Description | Study Design and Sampling | Inclusion/Exclusion Criteria | Study Definitions | Incidence/Prevalence | Quality Rating
Author: Aaron et al., 2002 Country: India Study period: NR Funding: Department of Community Health and Development, Christian Medical College Author industry relationship disclosures: NR | Design: Cross-sectional administered questionnaire Base population: Permanent residents of the Kaniambadi rural development block of Vellore district in Tamil Nadu Sampling frame: Residents of 7 representative villages as enumerated by census; menopausal participant selected then matched to premenopausal control in same age strata N sampled: NR N screened: NR N eligible: Menopausal: 100 Pre-menopausal: 100 N respondents: NR N included: Menopausal: 100 Pre-menopausal: 100 Age, mean ± SD: Menopausal: 46.6 ± 2.2 Pre-menopausal: 45.4 ± 2.3 Race/ethnicity: NR | Inclusion criteria: • women • age 40 to 49 Exclusion criteria: • hysterectomy Effective response: NR | Urgency: NR Frequency: NR | Prevalence of urgency, %: Menopausal: 18 Pre-menopausal: 8 Prevalence of frequency, %: Menopausal: 17 Pre-menopausal: 11 | Overall quality: Poor Internal validity score: 2, − External Validity Score: 2, − Sampling Method Described: + N sampled provided: − N eligible provided: − N included respondents: + Response Rate:^*^ NR Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: − Required frequency defined^*^: −
Author: Bogren et al., 1997 Country: Sweden Study period: NR Funding: NR Author industry relationship disclosures: NR | Design: Cross sectional mailed questionnaire Base population: Primary healthcare district in southwest Sweden Sampling frame: All residents N screened: Total: 458 Women: 225 N eligible: Total: 458 Women: 225 N respondents: Total: 419 Women: 216 N included: Total: 419 Women: 216 Age, %: 65: 100 Race/ethnicity: NR | Inclusion criteria: • adults •65 years old Exclusion criteria: NR Effective response, %: 96^ | UUI: NR | Prevalence UUI, %: 18.5 | Overall quality: Poor Internal validity score: 5, ++ External Validity Score: 1,− Sampling Method Described: + N sampled provided: + N eligible provided: + N included respondents: + Response Rate:^*^ 96 Inclusion (Exclusion) Specified: + Age of population described: 0? Operational definition provided^*^: − Required frequency defined^*^: −
Author: Bortolotti et al., 2000 Country: Italy Study period: March 1997 to October 1997 Funding: Pharmacia & Upjohn Italia Author industry relationship disclosures: At least 2 of 12 Pharmacia & Upjohn (2) | Design: Cross-sectional telephone questionnaire Base population: Registered participants in primary care networks in six areas of Italy Sampling frame: NR N sampled: NR N screened: NR N eligible: NR N respondents: Women: 2,767 N included: Women: 2,767 Age, %:^ 40–50: 22.6 51–60: 30.4 61–70: 19.8 > 70: 27.2 Race/ethnicity: NR | Inclusion criteria: • adults • women age ≥ 40 • men age ≥ 50 Exclusion criteria: NR Effective response, %: NR (“practically 100%”) | Incontinence: Loss of urine at least once in prior year UUI: NR SUI: NR MUI: NR | Prevalence of UUI, %:^*^ 1.4 Prevalence of MUI, %:^*^ 2.7 | Overall quality: Poor Internal validity score: 2, − External Validity Score: 3, + Sampling Method Described: + N sampled provided: − N eligible provided: − N included respondents: + Response Rate:^*^ NR Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: − Required frequency defined^*^: +
Author: Brieger et al., 1997 Yip and Chung, 2003 Country: Territory of Hong Kong Study period: May 1996 to November 1996 Funding: NR Author industry relationship disclosures: NR | Design: Cross-sectional telephone questionnaire Base population: Chinese women in Hong Kong Sampling frame: Multistage random sample of more than 1.7 million residential telephone listings in Hong Kong N screened: 3,509 N eligible: NR N respondents: 1,500 N included: 1,500 Age, mean ± SD: 45 ± 15 Race/ethnicity, %: Chinese: 100 BMI, mean ± SD: 22.4 ± 2.8 Parity, %: 83 | Inclusion criteria: • women • oldest of eligibles in household • ethnic Chinese Exclusion criteria: NR Effective response, %: 43 | UUI: NR MUI: NR Detrusor dysfunction: One or more of the following: UUI, urgency, frequency, or nocturia, in the absence of SUI Urgency: NR Frequency: NR | Prevalence of UUI, %: 0.7 Prevalence of MUI, %: 4.7 Prevalence of detrusor dysfunction, %: 2.4 Prevalence of urgency, %: 4.3 Prevalence of frequency, %: 4.2 | Overall quality: Poor Internal validity score: 4, + External Validity Score: 1, − Sampling Method Described: + N sampled provided: + N eligible provided: − N included respondents: + Response Rate:^*^ 43 Inclusion (Exclusion) Specified: + Age of population described: − Operational definition provided^*^: − Required frequency defined^*^: −
Author: Brieger et al., 1996 Country: Territory of Hong Kong Study period: NR Funding: NR Author industry relationship disclosures: NR | Design: Cross sectional telephone questionnaire (Kings College Urodynamics Questionnaire) Base population: Chinese women in Hong Kong Sampling frame: Multistage random sample of more than 1.7 million residential telephone listings in Hong Kong N screened: 3,248 N eligible: NR N respondents: NR N included: 819 Age, mean ± SD: 41.5 ± 16 Race/ethnicity: NR Parity, %: 66.9 | Inclusion criteria: • women • age between 10 and 90 • oldest of eligibles in household Exclusion criteria: NR Effective response, %: 25.2 | UI: Involuntary loss of urine that is socially or hygienically unacceptable UUI: NR Frequency: NR | Prevalence of urgency and/or UUI, %: 14.7 Prevalence of frequency, %: 18.8 | Overall quality: Poor Internal validity score: 3, − External Validity Score: 2, − Sampling Method Described: + N sampled provided: + N eligible provided: − N included respondents: + Response Rate:^*^ 25.2 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: − Required frequency defined^*^: −
Author: Chen, Lin, Hu et al., 2003 Chen, Chen, Hu et al., 2003 Country: Taiwan Study period: 1999 Funding: National Science Council in Taiwan Author industry relationship disclosures: NR | Design: Cross-sectional administered questionnaire(Bristol) Base population: Female residents of Dali Sampling frame: 3% random sample based on national census records to achieve nationally representative age strata N sampled: 1,584 N screened: NR N eligible: NR N respondents: 1,253 N included: 1,247 Age, mean ± SD: 43.2 ± 15.1 Race/ethnicity: NR BMI, mean ± SD: 23.1 ± 3.3 Parity, % 86.5 | Inclusion criteria: • women • age ≥ 20 Exclusion criteria: NR Effective response, %: 78.7 | UUI: Involuntary loss of urine preceded by the urge to void or relatively uncontrollable voiding with little or no warning, without requirement for “bother” or perceived social or hygienic problem. OAB: Frequency and urgency, or nocturia, with or without UUI Urgency: Per ICS 2002 Frequency: Per ICS 2002 Strict definitions:^*^ Above with requirement for “bother” and/or perceived social or hygienic problem | Prevalence of UUI, %: 9.1 Prevalence of UUI-strict, %: 1.5 Prevalence of MUI, %: 17.1 Prevalence of MUI by age, %: 20–30: 10.0 >30–40: 16.2 >40–50: 23.1 >50–65: 20.2 > 65: 16.6 P < 0.05 Prevalence of MUI-strict, %: 1.8 Prevalence of MUI-strict by age, %: 20–30: 0.8 >30–40: 0.5 >40–50: 3.5 >50–65: 3.7 > 65: 2.1 P < 0.05 Prevalence of OAB, % 18.6 Prevalence of OAB by age, % 20–30: 11.7 >30–40: 13.3 >40–50: 20.7 >50–65: 20.2 > 65: 39.3 P < 0.05 Prevalence of OAB-strict, % 2.5 Prevalence of OAB-strict by age, % 20–30: 0.9 >30–40: 0.5 >40–50: 1.5 >50–65: 4.8 > 65: 9.7 P < 0.05 Prevalence of urgency, %: 12.6 Prevalence of urgency-strict, %: 1.7 Prevalence of frequency, %: 21.1 Prevalence of frequency-strict, %: 2.3 | Overall quality: Fair Internal validity score: 4+ External Validity score: 3, + Sampling Method Described: + N sampled provided: + N eligible provided: − N included respondents: + Response Rate:^*^ 78.7 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: + Required frequency defined^*^: −
Author: Choo et al., 2007 Country: Korea Study period: 2000 Funding: Korean Continence Society-Johnson & Johnson Medical Author industry relationship disclosures: NR | Design: Cross-sectional telephone questionnaire Base population: Representative cross section of Korean population stratified by age, sex, and region Sampling frame: Random selection of telephone numbers N sampled/screened: 14,559 N eligible: Total: 2,005 Women: 1,005 Age, mean ± SD:^ 59.4 ± 11.6 Age, median:^ 59.0 Age, n (%):^ 40–49: 254 (25.3) 50–59: 252 (25.1) 60–69: 246 (24.5) ≥ 70: 253 (25.2) Race/ethnicity: NR | Inclusion criteria: • adults • age 40 to 89 • community-dwelling Exclusion criteria: None Effective response: NA | Urgency: “Do you have to rush to the toilet?” Frequency: “How often do you pass urine on average?” UUI: “When you have an urge to urinate, do you loose urine before you could reach the bathroom?” OAB: Per ICS OAB-dry:<br>Per ICS urge + freq; or urge + nocturia; or urge + freq + nocturia, without UUI OAB-wet: Any combination with UUI | Prevalence of UUI by age, %: All: 19.2 40–49: 13.0 50–59: 15.1 60–69: 24.4 ≥ 70: 24.5 Prevalence of OAB-wet by age, %: All: 15.0 40–49: 10.2 50–59: 11.9 60–69: 19.5 ≥ 70: 18.6 Prevalence of OAB-dry by age, %: All: 16.3 40–49: 16.9 50–59: 15.5 60–69: 14.2 ≥ 70: 18.6 Prevalence of urgency by age, %: All: 32.5 40–49: 29.1 50–59: 28.6 60–69: 35.0 ≥ 70: 37.5 Prevalence of frequency by age, %: All: 17.7 40–49: 16.5 50–59: 14.7 60–69: 17.1 ≥ 70: 22.5 | Overall quality: Fair Internal validity score: 3,− External Validity Score: 3,+ Sampling Method Described: + N sampled provided: + N eligible provided: + N included respondents: − Response Rate:^*^ NR Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: + Required frequency defined^*^: −
Author: Corcos and Schick, 2004 Country: Canada Study period: Spring 2002 Funding: Pfizer Novartis Author industry relationship disclosures: NR | Design: Cross-sectional telephone questionnaire Base population: Canada Sampling frame: Stratified random sample of census areas in four census metropolitan areas by gender from the telephone registry N sampled: Total: 7,487 N screened: NR N eligible: NR N respondents: Total: 3,249 Women: 1,683 N included: Total: 3,249 Women: 1,683 Age, %:^ 35–44: 35.6 45–54: 28.1 55–64: 17.0 65–74: 11.9 ≥ 75: 6.8 Race/ethnicity: NR | Inclusion criteria: • adults • age ≥ 35 Exclusion criteria: NR Effective response, %: 53.7 | OAB-wet (UUI): Urgency with urinary leaks OAB-dry (urgency): “Urgency with need to urinate that runs the risk of urine loss” at least weekly; or half the time or more it is “difficult to postpone urination” and they engage in bathroom seeking behavior. OAB: NR Frequency: ≥ 9 voids per day | Prevalence of OAB-wet, %: 6.5 Prevalence of OAB, %: 21.3 Prevalence of OAB by age, %: 35–44: 17.9 45–54: 21.1 55–64: 26.8 65–74: 24.0 ≥ 75: 21.4 Prevalence of urgency, %: 23.3 Prevalence of frequency, %: 15.5 | Overall quality: Fair Internal validity score: 4, + External Validity Score: 4, ++ Sampling Method Described: + N sampled provided: + N eligible provided: − N included respondents: + Response Rate:^*^53.7 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: + Required frequency defined^*^: −
Author: Dallosso et al., 2004 Country: UK Study period: October 1998 to December 1998^*^ Follow-up 1999 Funding: Medical Research Council Author industry relationship disclosures: NR | Design: Cross-sectional mailed questionnaire with repeated measures mailed food frequency (FFQ) questionnaire Base population: Patients registered in any of 108 general practices in Leicestershire Sampling frame: Random sample Leicestershire Health Authority registry N sampled: 20,247 N screened: NR N eligible: 19,241 N respondents: Baseline: 12,568 FFQ: 7,046 Follow-up FFQ: 5,816 N included: 5,816 Age, median: 61 Race/ethnicity: NR | Inclusion criteria: • women • age ≥ 40 • community dwelling Exclusion criteria: NR Effective response, %: 30.2 | OAB: Urge leakage at least several times a month and/or very strong or overwhelming urgency | Annual incidence of OAB, %: 8.8 Incidence of OAB by age, %: 40–49: 7.8 50–59: 6.5 60–69: 10.0 70–79: 11.7 ≥ 80: 14.3 Baseline prevalence of OAB, %: 15.9 Baseline prevalence of OAB by age, %: 40–49: 12.1 50–59: 15.4 60–69: 16.8 70–79: 18.5 ≥ 80: 26.1 | Overall quality: Fair Internal validity score: 4, + External Validity Score: 4, ++ Sampling Method Described: + N sampled provided: + N eligible provided: + N included respondents: + Response Rate:^*^ 30.2 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: + Required frequency defined^*^: +
Author: Dooley et al., 2008* Minassian et al., 2008 Country: US Study period: 2001 to 2004* 2001 to 2002 Funding: NR*, NR Author industry relationship disclosures: NR*, NR | Design: Cross-sectional administered questionnaire Base Population: NHANES a probability sample of the US non-institutionalized civilian population Sampling frame: NHANES participants N sampled: 21,161* 11,039 N screened: NA N eligible: 4,541* 2,875 N participants: 4,229* 2,577 Age, %:* 20–39: 36.3 40–59: 28.0 ≥ 60: 35.7 Age, mean ± SD: 50.8 ± 20.1 Race/ethnicity, %:* White: 57.9 Black: 20.5 Hispanic: 21.5 Race/ethnicity, %: White: 55 Black: 18 Hispanic: 24 Other: 3 BMI, kg/m^2^ n:* ≤ 25.0: 1,361 25.0–29.9: 1,320 30.0–39.9: 1,238 ≥ 40.0: 310 BMI, mean ± SD: 28.6 ± 6.8 | Inclusion criteria: • women • age 20 or older • answered the questions about incontinence Exclusion criteria: • ethnicity classified as “other”* Effective response: NA | UUI: in past 12 months, “leaked or lost control of even a small amount of urine with an urge or pressure to urinate and you could not get to a toilet fast enough” SUI: In past 12 months, “leaked or lost control of even a small amount of urine with an activity like coughing, lifting, or exercise.” MUI: affirmative response to both SUI and UUI. Severity of incontinence: Mild: few times a year Moderate: few times a month Severe: daily or few times a week | Prevalence of UUI, %:* 7.9 Prevalence of UUI, %: 8.8 Prevalence of UUI by Age, %:* 20–39: 4.6 40–59: 8.7 ≥ 60: 11.7 Severity of UUI, % Mild: 41 Moderate: 31 Severe: 57 Prevalence of MUI, %:* 17.0 Prevalence of MUI, %: 13.0 Prevalence of MUI by Age, %:* 20–39: 7.7 40–59: 18.6 ≥ 60: 28.7 Severity of MUI, % Mild: 13 Moderate: 31 Severe: 57 | Overall quality: Fair Internal validity score: 4, + External Validity Score: 4, ++ Sampling Method Described: + N sampled provided: + N eligible provided: + N included respondents: + Response Rate:* NR Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided*: + Required frequency defined*: +
Author: Ege et al., 2008 Country: Turkey Study period: May 2006 Funding: NR Author industry relationship disclosures: NR | Design: Cross-sectional administered questionnaire Base population: Female residents of Konya Sampling frame: All postpartum women registered in seven health centers in the metropolitan area N sampled: 2,200 N screened: NR N eligible: NR N respondents: 1,749 N included: 1,749 Age, mean ± SD: 26.8 ± 5.1 Race/ethnicity: NR BMI, mean ± SD: 25.9 ± 3.8 | Inclusion criteria: • women • within 12 months postpartum Exclusion criteria: • pregnant again at time of interview Effective response, %: 79.5 | UUI: NR SUI: NR MUI: NR | Prevalence of UUI postpartum, %: 2.0 Prevalence of MUI postpartum, %: 9.3 | Overall quality: Poor Internal validity score: 4, + External Validity Score: 1, − Sampling Method Described: + N sampled provided: + N eligible provided: − N included respondents: + Response Rate:* 79.5 Inclusion (Exclusion) Specified: + Age of population described: − Operational definition provided*: − Required frequency defined*: −
Author: Espino et al., 2003 Country: US Study period: Fall 1993 to Spring 1994 Funding: NIH Author industry relationship disclosures: NR | Design: Cross-sectional administered in-home interview Base population: Mexican-Americans, age ≥ 65 residing in southwestern states (AZ, CA, CO, NM, TX) Sampling frame: Representative probability sample from the Hispanic EPESE* N screened: NR N eligible: NR N respondents: 1,755 N included: 1,589 Age, mean ± SD: 73.3 ± 6.2 Race/ethnicity, %: Hispanic: 100 BMI: NR for total N | Inclusion criteria: • women • age ≥ 65 • community dwelling • Mexican-American Exclusion criteria: • individuals with indwelling catheters Effective response, %: 90.5 | UUI: Feeling need to urinate before loosing urine MUI: UUI and leaking urine during sneezing, coughing, vomiting, lifting, laughing or straining | Prevalence of UUI, %: 5.0 Frequency of UUI, %: Hardly ever: 17.7 Some of the time: 59.5 Most of the time: 13.9 All of the time: 8.9 Volume of urine loss UUI, %: Small: 50.0 Moderate: 39.5 Large: 10.5 Wear protection all the time UUI, %: 10.1 UUI Inhibits social activity, %: 16.7 Prevalence of MUI, %: 6.3 Frequency of MUI, %: Hardly ever: 12.0 Some of the time: 60.0 Most of the time: 18.0 All of the time: 10.0 Volume of urine loss MUI, %: Small: 59.2 Moderate: 31.6 Large: 9.2 Wear protection all the time MUI, %: 16.0 MUI Inhibits social activity, %: 21.0 | Overall quality: Fair Internal validity score: 3, + External Validity Score: 3, + Sampling Method Described: + N sampled provided: − N eligible provided: − N included respondents: + Response Rate:* 90.5 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided*: + Required frequency defined*: −
Author: Eva et al., 2003 Country: Sweden Study period: 1997 Funding: County of Östergötland (Folkshalsoanslaget); Linköping University Hospital Author -industry relationship disclosures: NR | Design: Cross-sectional mailed questionnaire Base population: Women in Östergötland born in 1937 or 1957 Sampling frame: 39% random sample of the base N screened: 2,000 N eligible: NR N respondents: 1,336 N included: 1,317 Age, n (%): 40-yr olds: 643 (48.8) 60-yr olds: 674 (51.2) Race/ethnicity: NR | Inclusion criteria: • women • born in designated years Exclusion criteria: NR Effective response, %: 65.9 | UUI: Urge to void before leaking | Prevalence of UUI, %: 40-yr olds: Sometimes: 11.3 Mostly: 2.1 60-yr olds: Sometimes: 15.1 Mostly: 5.2 Prevalence of daytime voids, Number %: 40-yr olds: 8–10: 4.2 > 10: 2.1 60-yr olds: 8–10: 7.8 > 10: 2.1 | Overall quality: Fair Internal validity score: 4, + External Validity Score: 3, + Sampling Method Described: + N sampled provided: + N eligible provided: − N included respondents: + Response Rate:* 65.9 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided*: + Required frequency defined*: −
Author: Fenner et al., 2008 Country: US Study period: Summer 2002 to Fall 2004 Funding: NIH Author industry relationship disclosures: 2 of 7: Johnson & Johnson (1) Novartis (1) Novasys (1) | Design: Cross-sectional telephone questionnaire Base population: Residents of 3 Michigan counties Sampling frame: Telephone listings from commercial survey sampling group N sampled: 12,541 N screened: 9,199 N eligible: 3,692 N respondents: 2,814 Age, %: 35–44: 40.6 45–54: 37.7 55–64: 21.7 Race/ethnicity, n (%): Black: 1,922 (68.3) White: 892 (31.7) Vaginally Parous, %: 69.3 | Inclusion criteria: • black or white women • age 35 to 64 • community dwelling Exclusion criteria: • pregnancy in last 12 months Effective response, %: 69 | Incontinence: Losing urine ≥ 12 times in 12 months UUI: based on at least one factor from urge component of factor analysis and no stress factors SUI: based on at least one factor from stress component of factor analysis | Prevalence of UUI, %: 3.6 Prevalence of UUI by race/ethnicity, %: Black: 3.5 White: 3.6 Prevalence of MUI, %: 6.0 Prevalence of MUI by race/ethnicity, %: Black: 4.1 White: 7.1 | Overall quality: Good Internal validity score: 5, ++ External Validity Score: 4, ++ Sampling Method Described: + N sampled provided: + N eligible provided: + N included respondents: + Response Rate:* 69 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided*: + Required frequency defined*: +
Author: Fitzgerald et al., 2006^ Thom et al., 2006 * Huang et al., 2006^†^ Country: US Study period: NR Funding: NIH Author industry relationship disclosures: 4 of 7^ Allergan (2) Eli Lilly (1) Novartis (1) Pfizer (3) Q-med(1) Watson (1) Yamanouchi (4) | Design: Cross-sectional Written questionnaire and in-person interview follow-up Base population: Members of Kaiser Permanente Northern Care California Sampling frame: Random sampling of women by age and race strata to achieve equal strata size for age and fixed ratios by race/ethnicity N screened: 10,230* N screened: 8,835* N eligible: 3,240 estimated N respondents: 2,109* N included: 2,109 1,348^†^ Age, mean ± SD: 56 ± 9 Asian: 53.2 ± 7.4^†^ White: 56.0 ± 9.1^†^ Race/ethnicity, %: White: 48 Black: 18 Latina: 17 Asian: 16 Race/ethnicity, %:^†^ White: 74 Asian: 26 BMI, mean ± SD: NR for total N Asian: 25.8 ± 4.8^†^ White: 28.0 ± 6.7^†^ Parity, %: Total: 80 White: 80.8^†^ Asian: 79.3^†^ | Inclusion criteria: • women • age 40 to 69 • members since age 18 • ≥ 50% births with Kaiser Exclusion criteria: • race/ethnicity other than White or Asian^†^ Effective response, %: 65.1 | Urgency: Strong urge or pressure to urinate without actually leaking, at least monthly Frequency: ≥ 7 voids/day; NR^†^ UUI: NR, at least weekly; At least weekly incontinence with only or predominantly urge episodes in the last 7 days^†^ UUI only:* NR, at least weekly MUI: NR, at least weekly MUI, predominantly urge:* NR, at least weekly MUI, equal stress and urge:* NR, at least weekly | Prevalence of UUI, %: 10 Prevalence of UUI, %:^†^ Asian: 7.3 White: 9.5 P=.04 Prevalence of UUI only, age-adjusted, by race/ethnicity, % (95%CI):* White: 4.8 (3.9, 5.7) Hispanic: 5.8 (4.8, 6.8) Black: 7.6 (6.5, 8.8) Asian-American: 3.0 (2.3, 3.8) P = 0.027 Prevalence of MUI, %: 5 Prevalence of MUI, predominantly urge, by race/ethnicity, % (95%CI):* White: 4.0 (3.1, 4.8) Hispanic: 4.2 (3.3, 5.0) Black: 6.0 (5.0, 7.1) Asian-American: 4.4 (3.5, 5.2) P = NS Prevalence of MUI, predominantly urge, by race/ethnicity, % (95%CI):* White: 3.3 (2.5, 4.1) Hispanic: 5.3 (4.3, 6.3) Black: 1.9 (1.3, 2.5) Asian-American: 3.2 (2.5, 4.0) P = NS Prevalence of urgency, %: 34 Prevalence of frequency, %: 24% Prevalence of daily frequency, %:^†^ Asian: 7.8 White: 13.0 Prevalence of weekly frequency, %:^†^ Asian: 10.6 White: 17.8 P<.01 | Overall quality: Good Internal validity score: 5, ++ External Validity Score: 4, ++ Sampling Method Described: + N sampled provided: + N eligible provided: + N included respondents: + Response Rate:* 65.1 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided*: + Required frequency defined*: +
Author: Hannestad et al., 2000 Rortveit et al., 2003* Country: Norway Study period: 1995 to 1997 Funding: National Health Screening Service of Norway; National Institute of Public Health; Norwegian University of Science and Technology; Research Council of Norway Author industry relationship disclosures: NR | Design: cross-sectional mailed questionnaire (EPINCONT) Base population: Nord-Tr⊘ndelag County Sampling frame: All female residents of county; All women with vital records linkage* N sampled: 47,313 N screened: NR N eligible:^ 34,755 Birth substudy:* 15,307 N respondents:^ 27,936 Birth substudy:* 15,307 N included: 27,936 Birth substudy:* 15,307 Age, %: 20–24: 6.7 25–29: 7.6 30–34: 8.9 35–39: 9.7 40–44: 10.5 45–49: 10.7 50–54: 9.9 55–59: 7.3 60–64: 6.6 65–69: 6.6 70–74: 6.4 75–79: 5.1 80–84: 2.7 85–89:1.0 ≥ 90: 0.2 Age, birth substudy, %:* 20–24: 12.1 25–29: 13.0 30–34: 14.0 35–39: 15.4 40–44: 16.9 45–49: 16.5 50–54: 8.7 55–59: 2.2 60–64: 1.2 Race/ethnicity: NR BMI birth sub-study kg/m^2^, %:* < 25.0: 54.2 25.5–29.0: 32.9 ≥ 30: 12.9 | Inclusion criteria: • women • age ≥ 20 • community dwelling Birth substudy: • no births, only cesareans, or only vaginal births of singletons* Exclusion criteria: NR; Birth substudy:* • more than four children (no women had more than four cesareans) • births prior to 1967 (start of compulsory birth registration) • age ≥ 65 (birth records not consistently accurate) Effective response, %: 80.4% | UUI: Any loss of urine with sudden and strong urge to go to the toilet SUI: Any loss of urine with coughing, sneezing, laughing, lifting, etc. MUI: Both UUI and SUI | Prevalence of UUI, %:^**^ 2.7 Prevalence of UUI by age, %:^**^ 20–24: 1.3 25–29: 1.9 30–34: 1.8 35–39: 1.5 40–44: 1.9 45–49: 2.0 50–54: 2.1 55–59: 2.5 60–64: 2.6 65–69: 4.4 70–74: 4.8 75–79: 6.4 80–84: 7.4 85–89: 8.0 ≥ 90: 4.8 Prevalence of UUI, by birth type, %:* None: 1.6 Cesarean: 2.2 Vaginal: 1.8 P = NS Prevalence of MUI, %:^**^ 8.8 Prevalence of MUI by age, %:^**^ 20–24: 3.4 25–29: 4.0 30–34: 4.9 35–39: 6.1 40–44: 6.9 45–49: 7.7 50–54: 10.9 55–59: 10.2 60–64: 12.1 65–69: 70–74: 75–79: 80–84: 85–89: ≥ 90: Prevalence of MUI, by birth type, %:* None: 3.1 Cesarean: 5.5 Vaginal: 6.8 P vaginal compared to none:* P < 0.05 P vaginal compared to cesarean:* P = NS | Overall quality: Fair Internal validity score: 5, ++ External Validity Score: 3, + Sampling Method Described: + N sampled provided: + N eligible provided: + N included respondents: + Response Rate:* 80.4 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided*: + Required frequency defined*: −
Author: Herschorn et al., 2008 Country: Canada Study period: October 2002 Funding: Janssen-Ortho Canada Author industry relationship disclosures: 3 of 4 Astellas (1) Gynecare (1) Janssen-Ortho (3) Pfizer (2) Purdue (1) Triton (2) | Design: Cross-sectional telephone questionnaire in English or French Base population: Representative cross section of Canadian population stratified by age, sex, province, and census division Sampling frame: Modified random-digit dialing N sampled: NA N screened: 2,500 N eligible: Total: 1,000 Women: 518 Age, mean ± SD:^ 44.5 ± 17.2 Age, %:^ 18–40: 42.8 41–64: 45.8 ≥ 65: 11.4 Race/ethnicity: NR | Inclusion criteria: • adults • age 18 or older • community dwelling Exclusion criteria: • institutionalized men and women Effective response: NR | OAB: Per ICS Urgency: Per ICS Frequency: Per ICS UUI: Per ICS | Prevalence of UUI, %: Total (any): 9.3 ≤ 1x/wk: 5.0 2–3x/wk: 1.4 ~1x/day: 1.0 Several x/day: 0.8 All the time: 0.6 Prevalence of UUI by age, %: 18–40: 4.6 41–64: 10.7 ≥ 65: 22.4 Prevalence of OAB, %: 14.7 Prevalence of OAB by age, %: 18–40: 12.8 41–64: 13.7 ≥ 65: 27.5 Prevalence of urgency, %: Total (any): 14.1 ≤ 1x/wk: 4.4 2–3x/wk: 2.9 ~1x/day: 3.7 Several x/day: 2.0 All the time: 1.2 Prevalence of urgency by age, %: 18–40: 13.3 41–64: 14.2 ≥ 65: 19.0 Prevalence of frequency, %: 14.9 Prevalence of frequency by age, %: 18–40: 15.1 41–64: 13.3 ≥ 65: 22.4 | Overall quality: Poor Internal validity score: 2, − External Validity Score: 3, + Sampling Method Described: + N sampled provided: − N eligible provided: + N included respondents: − Response Rate:^*^ NR Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: + Required frequency defined^*^: −
Author: Herzog et al., 1990 Country: US Study period: 1983 to 1986^*^ Funding: NIH Author industry relationship disclosures: NR | Design: Baseline with follow-up telephone questionnaire Base population: Residents of Washtenaw County Sampling frame: Multistage stratified random sample of households N screened: Total: 13,912 N eligible: Total: 2,968 Women: NR N respondents: 1,956 N included:^ Baseline: 1,154 One-Yr: 1,056 Two-Yrs: 776 Age, %: NR Race/ethnicity: NR | Inclusion criteria: • adults • age ≥ 60 Exclusion criteria: NR Effective response, %: Total: 65.9 | UUI: Urine loss preceded by urge to void or uncontrollable voiding with little or no warning SUI: Urine loss at times of exertion such as sneezing, lifting, bending MUI: Both UUI and SUI | Annual incidence of UUI, %: Baseline to Yr1: 1.7 Yr1 to Yr2: 1.5 Annual incidence of MUI, %: Baseline to Yr1: 9.8 Yr1 to Yr2: 5.4 Annual remission of UUI, %: Baseline to Yr1: 22.7 Yr1 to Yr2: 24.0 Annual remission of MUI, %: Baseline to Yr1: 4.8 Yr1 to Yr2: 8.6 Baseline prevalence of UUI, %: 2.8 Baseline prevalence of MUI, %: 21.2 | Overall quality: Fair Internal validity score: 5, ++ External Validity Score: 3, + Sampling Method Described: + N sampled provided: + N eligible provided: + N included respondents: + Response Rate:^*^ 65.9 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: + Required frequency defined^*^: −
Author: Homma et al., 2005 Homma et al., 2006 Country: Japan Study period: November 2002 to March 2003 Funding: NR Author industry relationship disclosures: None | Design: Cross-sectional mailed questionnaire Base population: Population of Japan age ≥ 40 Sampling frame: Two-stage random sample of households N sampled: 10,096 N screened: NA N returned: 4,605 N participants: Total: 4,570 Women: 2,380 Age, mean (range):^ 61 (41,100) Race/ethnicity: NR | Inclusion criteria: • adults • age ≥ 40 Exclusion criteria: NR Effective response, %: Total: 45 Women: NR | OAB: ≥8 voids per day and ≥1 episode of urgency/week UUI: ICS definition Frequency: ≥ 8 voids per day Frequency: ≥ 11 voids per day Urgency: ICS definition per day or week | Prevalence of UUI, %: 7 Prevalence of OAB, %: 11 Prevalence of UUI and OAB by age: Prevalence of both types increase with age. P=NS Prevalence of urgency ≥ 1/day, %: 7 Prevalence of urgency ≥ 1/wk, %: 13 Prevalence of frequency ≥ 8/day, %: 49 Prevalence of frequency ≥ 11/day, %: 10 | Overall quality: Fair Internal validity score: 4, + External Validity Score: 4, ++ Sampling Method Described: + N sampled provided: + N eligible provided: − N included respondents: + Response Rate:^*^ 45 Inclusion (Exclusion) Specified: + Age of population described: Operational definition provided^*^: + Required frequency defined^*^: +
Author: Hording et al., 1986 Country: Denmark Study period: April 1981 to July 1982 Funding: The Legacy of Emmy Lange, née Kramp, Rahbek Foundation Author industry relationship disclosures: NR | Design: Cross-sectional administered questionnaire Base population: Female residents of the Glostrup area of Copenhagen county born in 1936 Sampling frame: All women born in 1936 and living in the Glostrup area N sampled: 613 N screened: NR N respondents: 528 N included: 515 Age: 45 Race/ethnicity: NR Parity, %: 93 | Inclusion criteria: • Women • Age 45 Exclusion criteria: NR Effective response, %: 85 | UUI: Involuntary loss of urine following a pathologically strong desire to void SUI: Urine loss accompanying coughing, laughing, sneezing, running, or jumping with a full bladder or during sexual intercourse MUI: Mixture of UUI and SUI | Prevalence of UUI, %: 5.4 Prevalence of MUI, %: 3.1 | Overall quality: Fair Internal validity score: 4, + External Validity Score: 4, ++ Sampling Method Described: + N sampled provided: 1 N eligible provided: +-N included respondents: + Response Rate:^*^ 85 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: Required frequency defined^*^: −
Author: Hsieh et al., 2006 Country: Taiwan Study period: NR Funding: NR Author industry relationship disclosures: NR | Design: Cross-sectional administered questionnaire Base population: Female residents of Taiwan Sampling frame: Three stage random sample: township, block, individual to obtain nationally representative sample N sampled: NR N screened: NR N eligible: 4,546 N respondents: 3,537 N included: 3,519 Age, %: 20–29: 27.1 30–39: 29.8 40–49: 26.5 50–59: 16.6 Race/ethnicity: NR | Inclusion criteria: • women • age 20 to 59 Exclusion criteria: NR Effective response, %: 77.4 | Frequency: “void too often during the day” | Prevalence of frequency, %: 5.2 Prevalence of frequency, voids per day, %: 8–15: 2.4 16–23: 1.9 24–31: 0.05 ≥ 32: 0.7 Prevalence of frequency by age, %: 20–29: 4.7 30–39: 5.8 40–49: 5.2 50–59: 5.9 P = 0.33 | Overall quality: Poor Internal validity score: 4, + External Validity Score: 2, − Sampling Method Described: + N sampled provided: − N eligible provided: + N included respondents: + Response Rate:^*^ 77.4 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: − Required frequency defined^*^: −
Author: Iosif and Bekassy, 1984 Country: Sweden Study period: NR Funding: NR Author industry relationship disclosures: NR | Design: Cross-sectional mailed questionnaire Base population: Malmöhus County, Sweden Sampling frame: Approximately 3,000 female residents born in 1921 N sampled: 1,200 N screened: NA N eligible: NA N respondents: 902 Age: NR Race/ethnicity: NR | Inclusion criteria: • women • born in 1921 Exclusion criteria: NR Effective response, %: 75 | UUI: “do you usually get such a very strong urge that you cannot hold back until you reach a toilet?” MUI: Combination of urge and stress (“involuntary loss of urine when cough, laugh,” etc) incontinence | Prevalence UUI, %: 8.0 Prevalence MUI, %: 9.5 | Overall quality: Fair Internal validity score: 4, + External Validity Score: 2 − Sampling Method Described: + N sampled provided: + N eligible provided: − N included respondents: + Response Rate:^*^ 75 Inclusion (Exclusion) Specified: + Age of population described: − Operational definition provided^*^: + Required frequency defined^*^: −
Author: Irwin et al., 2006 Country: Canada, Germany, Italy, Sweden, UK Study period: April 2005 to December 2005 Funding: Pfizer Author industry relationship disclosures: 10 of 11 Astellas (5) Bayer (1) Boehringer-Ingelheim (1) Diagnostic Ultrasound (1) Ferring (1) Janssen-Ortho (1) Lilly (2) Novartis (3) Paladin (1) Pfizer (10) Plethora (1) Schwarz-Pharma (1) Tena (1) UCB (1) Yamanouchi (1) | Design: Cross-sectional telephone questionnaire (EPIC) Base population: Residents of Canada, Germany, Italy, Sweden, UK Sampling frame: Two-step random sampling of households and individuals via residential telephone N screened: 58,139 N eligible: NR N respondents: 19,165 N included: Total: 19,165 Women: NR Age, %:^ 18–29: 13.6 30–34: 7.5 35–39: 10.2 40–44: 11.7 45–49: 10.5 50–54: 9.7 55–59: 9.2 60–64: 7.0 ≥ 70: 12.5 Race/ethnicity, %: White: 95.6 | Inclusion criteria: • adults • age ≥ 18 • most recent birthday in household Exclusion criteria: NR Effective response, %: 33 | Urgency: Per ICS 2002 Frequency: Per ICS 2002 UUI: Per ICS 2002 MUI: Per ICS 2002 | Prevalence of UUI, % (95% CI): 1.5 (1.2, 1.7) Prevalence of UUI by age, % (95% CI): ≤ 39: 1.0 (0.6, 1.3) 40–59: 1.1 (0.7, 1.5) ≥ 60: 2.5 (1.9, 3.0) Prevalence of MUI, % (95% CI): 2.4 (2.1, 2.7) Prevalence of MUI by age, % (95% CI): ≤ 39: 1.0 (0.6, 1.3) 40–59: 2.4 (1.9, 3.0) ≥ 60: 4.1 (3.4, 4.8) Prevalence of urgency, % (95% CI): 12.8 (12.2, 13.5) Prevalence of urgency by age, % (95% CI): ≤ 39: 9.7 (8.8, 10.7) 40–59: 11.2 (10.1, 12.3) ≥ 60: 18.3 (16.9, 19.6) Prevalence of frequency, % (95% CI): 7.4 (6.9, 7.9) Prevalence of frequency by age, % (95% CI): ≤ 39: 7.9 (7.0, 8.8) 40–59: 5.8 (5.0, 6.6) ≥ 60: 8.4 (7.5, 9.4) | Overall quality: Fair Internal validity score: 4, + External Validity Score: 4, ++ Sampling Method Described: + N sampled provided: + N eligible provided: − N included respondents: + Response Rate:^*^ 33 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: − Required frequency defined^*^: −
Author: Ju, et al. 1991 Country: Singapore Study period: July 1989 to November 1989 Funding: National University of Singapore Author industry relationship disclosures: NR | Design: Cross-sectional dministered questionnaire, with follow-up interview if incontinent Base population: Elderly residents of a postal district in Telok Blangah Housing Estate Sampling frame: All elderly people in Ministry of Home Affairs registry for study district N sampled: 1,511 N eligible: 1,143 N respondents: 919 N included: Total: 919 Women: 484 Age: NR by gender Race/ethnicity: NR by gender | Inclusion criteria: • Adults • Age ≥ 65 Exclusion criteria: NR Effective response, %: 80.4 | Incontinence: Leakage of urine two or more times in the past month UUI: Urine loss because of inability to delay voiding following an urge to micturition SUI: Urine loss associated with increases in intra-abdominal pressure (physical exertion, straining, coughing, or laughing) MUI: NR | Prevalence of UUI, %: 3.3 Prevalence of UUI, %: 0.8 | Overall quality: Fair Internal validity score: 4, + External Validity Score: 4,++ Sampling Method Described: + N sampled provided: + N eligible provided: + N included respondents: + Response Rate:^*^ 82 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: + Required frequency defined^*^: −
Author: Kay et al., 1999 Country: Denmark Study period: NR Funding: Gammelgårds Grant, Synthélabo Scandinavia Author industry relationship disclosures: NR | Design: Cross-sectional mailed questionnaire (DAN-PPS) Base population: Population of Herlev municipality Sampling frame: Gender and age stratified random sample of adults in age range N sampled: Total: 500 Women: 250 N screened: NA N eligible: NR N respondents: All: 368 Women: 158 Age, n:^ 40–49: 33 50–59: 40 60–69: 28 70–79: 36 80–89: 21 Age, mean:^ 62.5 Age, median (range):^ 61 (41, 89) Race/ethnicity: NR | Inclusion criteria: • adults • age 40 to 89 Exclusion criteria: NR Effective response, %: All: 74 Women: 63 | All measures are for two week window UUI: NR Urgency: NR Frequency: NR | Prevalence of UUI, % (95% CI): 25.3 (18.9, 33.0) Prevalence of urgency, % (95% CI): 67.1 (59.1, 74.2) Prevalence of frequency, % (95% CI): 42.2 (34.7, 50.5) | Overall quality: Fair Internal validity score: 4, + External Validity Score: 3,+ Sampling Method Described: + N sampled provided: + N eligible provided: − N included respondents: + Response Rate:^*^ 63 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: − Required frequency defined^*^: +
Author: Kim et al., 2006 Country: US Study period: 2000 Funding: Pfizer Author industry relationship disclosures: 5 of 5 Pfizer (5) | Design: Database linkage study Base population: US population Sampling frame: National Ambulatory Medical Care Survey, National Hospital Ambulatory Medical Care Survey, National Hospital Discharge Survey data for 2000 N sampled: NR N screened: NR N eligible: NR N respondents: NR N included: NR Age: NR | Inclusion criteria: • adults • age ≥ 18 • first three coded diagnoses per care episode Exclusion criteria: NR Effective response: NA | OAB visits: ICD-9: 788.31, 788.41 and 788.33 Frequency: coded indication for visit. Urge incontinence: Coded indication for visit. Prevalence: expressed as number of adults with visit type per 10,000 adult population weighted for gender based on 2000 census. | National annual OAB visits: 1.4 million (1.1, 1.8) Prevalence of visits for UUI: 16 per 10,000 adults Prevalence of visits for MUI: 5 per 10,000 adults Prevalence of visits for any OAB symptom: Women: 81/10,000 Men: 56/10,000 Prevalence of visits for frequency: 48 per 10,000 adults | Overall quality: Fair Internal validity score: (+) External Validity Score: 2, − Sampling Method Described: + N sampled provided: NA N eligible provided: NA N included respondents: NA Response Rate:^*^ NA Inclusion (Exclusion) Specified: + Age of population described: − Operational definition provided^*^: + Required frequency defined^*^: −
Author: Koyama et al., 1998 Country: Japan Study period: NR Funding: NR Author industry relationship disclosures: NR | Design: Cross-sectional mailed questionnaire Base population: Residents of the selected farming village or suburban town Sampling frame: Distribution to all residents, 970 in village; 1,508 in suburb N sampled: Village: 970 Suburb: 1,508 N screened: NA N eligible: NA N respondents: Village: 937 Suburb: 934 Women: 1,120 Age, %: 60–69^*^: 31.7 70–79: 47.9 ≥ 80: 20.4 Race/ethnicity: NR | Inclusion criteria: • adults • age > 65 • community dwelling Exclusion criteria: NR Effective response, %: Village: 98.4 Suburb: 65.0 | Incontinence: “even a small amount of urinary leakage at a time when there was no intention of urinating.” UUI: Not specified, however “urgency” subtype presented | Prevalence of UUI, %: Women: 5.3^**^ | Overall quality: Poor Internal validity score: 4, + External Validity Score: 2, − Sampling Method Described: + N sampled provided: + N eligible provided: − N included respondents: + Response Rate:^*^ >65 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: − Required frequency defined^*^: −
Author: Kuh et al., 1999 Country: UK Study period: 1993 to 1994 Funding: Medical Research Council Author industry relationship disclosures: None | Design: Cross-sectional mailed questionnaire Base population: Women in the UK Sampling frame: Members of the Medical Research Council National Survey of Health and Development a nationally representative birth cohort begun in March 1946 N sampled: 1,486 N screened: NR N eligible: 1,486 N respondents: 1,378 N included: 1,333 Age, %: 48: 100% Race/ethnicity: NR BMI kg/m^2^, %: < 20: 7.2 20.1–25.0: 55.9 25.1–30.0: 25.0 > 30.0: 12.0 Vaginally parous, %: 81.7 | Inclusion criteria: • women • born in March 1946 • members of cohort Exclusion criteria: NR Effective response, %: 89.7 | UUI: Urgent and strong desire to pass urine which is difficult to control and ever any loss of urine before getting to toilet SUI: Loss of urine when you cough, sneeze, laugh, run, or exercise MUI: Both UUI and SUI | Prevalence of UUI, %: 22 Prevalence of MUI, %: 20 | Overall quality: Fair Internal validity score: 5, ++ External Validity Score: 3, + Sampling Method Described: + N sampled provided: + N eligible provided: + N included respondents: + Response Rate:* 89.7 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided*: + Required frequency defined*: −
Author: Lara and Nacey, 1994 Country: New Zealand Study period: NR Funding: Wellington Medical Research Foundation Author industry relationship disclosures: NR | Design: Cross-sectional mailed questionnaire Base population: Female residents of three areas of central Wellington Sampling frame: Random sample of the electoral roll N sampled: 1,028 N screened: NA N eligible: NA N respondents: 556 Age, mean (range): Maoris: 39.1 (18, 95) Pacific Islanders: 34.9 (18, 79) Europeans: 47 (18, 90) Race/ethnicity, %: Maoris: 25.7 Pacific Islanders: 21.9 Europeans: 52.3 | Inclusion criteria: • women on electoral roll Exclusion criteria: NR Effective response, %: 54 | Incontinence definition: “any involuntary loss of urine” UUI: “sudden involuntary loss” MUI: Elements of UUI and stress (“loss with increased intraabdominal pressure”) | Prevalence of UUI, %: 9.2 Prevalence of MUI, %: 7.4 | Overall quality: Fair Internal validity score: 4, + External Validity Score: 2, − Sampling Method Described: + N sampled provided: + N eligible provided: − N included respondents: + Response Rate:* 54 Inclusion (Exclusion) Specified: − Age of population described: + Operational definition provided*: + Required frequency defined*: −
Author: Link et al., 2007 Hall et al., 2008 Country: US Study period: 2002 to 2005 Funding: NIH Author industry relationship disclosures: NR | Design: Cross-sectional administered questionnaire Base population: Residents of 16/17 Boston residential planning districts* Sampling frame: Two-stage random sample stratified to achieve gender and race/ethnicity representation N screened: 24,063 households* 9,066 individuals* N eligible: 8,702* N respondents: 5,506* N included: Total: 5,506 Women: 3,205* Age, %:^ 30–39: 24.7* 40–49: 26.2* 50–59: 24.3* 60–79: 24.7* Race/ethnicity, n (%):^ Black: 1,070* (33.4) White: 1,024* (32.0) Hispanic: 1,111* (34.7) | Inclusion criteria: • adults • age 30 to 79 • community dwelling Exclusion criteria: NR Effective response, %: 57.3* | Frequency: Needed to urinate again < 2hrs after urinating (fairly often, usually, almost always) and/or frequent urination during the day (fairly often, usually, almost always) and/or on average 8 or more urinations per day Urgency: Difficulty postponing urination (fairly often, usually, almost always) and/or strong urge or pressure to urinate immediately with little or no warning (fairly often, usually, almost always) and/or strong urge to urinate immediately whether or not they urinated or leaked urine (several times, many times per day) † Cluster analysis groupings: Four symptomatic clusters emerged which cannot be readily mapped to clinically useful tool/descriptors. | Prevalence of urgency, %: 14.2 Prevalence of frequency, %: 36.9 | Overall quality: Fair Internal validity score: 5, ++ External Validity Score: 3, + Sampling Method Described: + N sampled provided: + N eligible provided: + N included respondents: + Response Rate:* 57.3 Inclusion (Exclusion) Specified: + Age of population described:+ Operational definition provided*: + Required frequency defined*: −
Author: Liu and Andrews, 2002 Country: Australia Study period: 1992 to 1994 Funding: NR Author industry relationship disclosures: NR | Design: Repeated measures telephone questionnaire Base population: Residents of Southern Australia Sampling frame: Random sample, stratified by age from the State Electoral Data Base for South Australia N sampled: 4,184^*^ N screened: NR N eligible: 2,272 N respondents: 2,087 N included: 2,087 Age: “sample size of more than 190 in each gender and age group [70–74, 75–79,80–84,≥ 85]” Race/ethnicity: NR | Inclusion criteria: • adults • age ≥ 70 Exclusion criteria: NR Effective response, %: 49.9 | UUI: NR, “at least occasionally” SUI: NR, “at least occasionally” Mixed: Both UUI and SUI, “at least occasionally” | Annual Incidence of UUI, %: 22.6 Two-Year Incidence of UUI, %: 37.5 Prevalence of UUI by year, %:^**^ Yr 1: 18.2 Yr 2: 16.1 Yr 3: 21.2 Prevalence of MUI by year, %:^**^ Yr 1: 23.2 Yr 2: 26.5 Yr 3: 26.8 | Overall quality: Fair Internal validity score: 4, + External Validity Score: 2, − Sampling Method Described: + N sampled provided: + N eligible provided: + N included respondents: + Response Rate:^*^ 49.9 Inclusion (Exclusion) Specified: + Age of population described:− Operational definition provided^*^: + Required frequency defined^*^: −
Author: Lukacz et al., 2006 Lawrence et al., 2007^ Lawrence et al., 2008^†^ Country: US Study period: April 2004 to January 2005 Funding: NIH NIH; Kaiser Permanente Direct Community Benefit Funds^^†^ Author industry relationship disclosures: † 2 of 5 Astellas (1) Novartis (1) Pfizer (2) Watson (1) | Design: Cross-sectional mailed questionnaire (EPIQ*) Base population: Kaiser Permanente Southern California members Sampling frame: Age-stratified random sample of 950,000 female members in age range in April 2004 N sampled: 12,200 N eligible: 12,200 N respondents: 4,458 N included: 4,103 3,962^ Age, mean ± SD: 56.5 ± 15.8 56.6 ± 15.8^ Race/ethnicity, %: White: 61.0 Hispanic: 19.4 Black: 9.7 Asian/Pacific: 7.9 Other: 2.1 Race/ethnicity, %:^ White: 61.7 Hispanic: 19.2 Black: 9.6 Asian/Pacific: 8.2 Other/unknown: 1.3 BMI, mean ± SD: <br>27.4 ± 6.3 27.8 ± 6.2^ Parity, %: 80.8 Vaginally Parous, %:^ 71.6 | Inclusion criteria: • women • age 25 to 84 • address on record with HMO Exclusion criteria: • insufficient data to categorize Effective response, %: 33.6 32.5^ | OAB: Per EPIQ* OAB-any: Includes urgency and frequency, with or without incontinence OAB-wet: Includes urgency and frequency, with incontinence SUI: Per EPIQ* | Prevalence of OAB-any, % (95% CI): 13.3 (12.2, 14.4) Prevalence of OAB-any by age, %:^†^ 25–39: 5.9 40–54: 10.9 55–69:14.8 70–84: 19.0 P<0.01 Prevalence of OAB, %:^ All: 13.4 Nondiabetic: 12.5 Diabetic: 21.4 P<0.0001 for diabetic vs. non Prevalence of OAB by parity, % (95% CI): Nulliparous: 9 (7, 11) Cesarean: 9 (7, 13) Vaginal: 15 (14, 16) P<0.05 both comparisons to vaginal Prevalence of OAB-wet, % (95% CI): † 12.7 (11.7, 13.9) Prevalence of mixed OAB-wet and SUI, % (95% CI): † 8.3 (7.5, 9.2) | Overall quality: Fair Internal validity score: 5, ++ External Validity Score: 3, + Sampling Method Described: + N sampled provided: + N eligible provided: + N included respondents: + Response Rate:* 34 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided*: + Required frequency defined*: −
Author: MacDiarmid and Rosenberg, 2005 Country: US Study period: September 2004 Funding: Ortho-McNeil Author industry relationship disclosures: 2 of 2 GlaxoSmithKline (1) Lilly (1) Novartis (1) Odyssey (1) Ortho-McNeil (2) Pfizer (2) Reliant (1) Watson (1) Yamanouchi (1) | Design: E-mailed invitation to online questionnaire Base population: Adult members of a multi-million- member online panel Sampling frame: Random electronic mailing N eligible: 2,951 N respondents: 2,951 Age: NR for total N Race/ethnicity: NR for total N BMI: NR for total N Parity: NR for total N | Inclusion criteria: • women • age ≥ 30 Exclusion criteria: NR Effective response: NR | UUI: ICS definition MUI: ICS definition | Prevalence of UUI, %: 9.2^*^ Prevalence of MUI, %: 13.2^*^ | Overall quality: Poor Internal validity score: 2, − External Validity Score: 2, − Sampling Method Described: + N sampled provided: − N eligible provided: + N included respondents: + Response Rate:^*^ NR Inclusion (Exclusion) Specified: + Age of population described: − Operational definition provided^*^: + Required frequency defined^*^: −
Author: McGrother et al., 2006^ Donaldson et al., 2006^*^ Country: UK Study period: Baseline questionnaires mailed in 1998^*^ Funding: Medical Research Council Author industry relationship disclosures: None | Design: Repeated measures mailed questionnaires at baseline and 1, 2^*^, and 3^*^-year follow- up Base population: Leicestershire Health Authority (108 general practices) Sampling frame: Random sample from 20,247 women on registers at baseline N eligible: 19,241 N respondents: Baseline: 12,750 Follow-up: NR Year 1: NR Year 2: NR Year 3: NR Age, mean ± SD: 59.5 ± 13.0^*^ Race/ethnicity, %: White: 85.5^*^ BMI kg/m^2^, %:^ < 20: 3.2 > 20–25: 38.7 > 25–30: 38.6 > 30: 19.5 Parity, %: 87.2^*^ | Inclusion criteria: • women • age ≥ 40 • community dwelling Exclusion criteria: NR^; • very elderly people in residential care;^*^ Effective Response, %: Baseline: 65.3 Follow-up: 79.7^ Year 1: 76.4^*^ Year 2: 71.2^*^ Year 3: 67.0^*^ | OAB: “a strong desire to pass urine resulting in leakage or urgency occurring monthly or more.” (exclusive of SUI)^ Very strong or overwhelming urgency and UUI several times a month or more^*^ UUI: strong desire to pass urine resulting in leakage before reaching toilet(exclusive of SUI) MUI:^ Not explicitly defined | Annual incidence of MUI, %:^ 4.5 Annual incidence of OAB, %:^ 5.4 Year 1 Incidence of OAB, %:^*^ 6.9 Year 1 Incidence OAB by age, %:^*^ 40–49: 6.7 50–59: 6.5 60–69: 7.0 70–79: 6.9 80+: 9.5 Year 1 Remission of OAB, %:^*^ 38.8 Year 1 Remission OAB by age, %:^*^ 40–49: 36.3 50–59: 32.9 60–69: 45.4 70–79: 39.7 80+: 45.9 Year 2 Incidence of OAB, %:^*^ 6.0 Year 2 Remission of OAB, %:^*^ 38.9 Year 3 Incidence of OAB, %:^*^ 6.8 Year 3 Remission of OAB, %:^*^ 36.9 Baseline prevalence of MUI, %:^ 12.7 Baseline prevalence of OAB, %:^ 7.7 Baseline prevalence of OAB by age, %:^*^ 40–49: 11.4 50–59: 14.060–69: 12.5 70–79: 12.1 80+: 15.5 | Overall quality: Fair Internal validity score: 4, + External Validity Score: 4, ++ Sampling Method Described: + N sampled provided: + N eligible provided: + N included respondents: − Response Rate:^*^ + Inclusion(Exclusion) Specified: + Age of population described: + Operational definition provided^*^: + Required frequency defined^*^: +
Author: Milsom et al., 2001 Country: France, Germany, Italy, Spain, Sweden, UK Study period: NR Funding: Pharmacia Corporation Author industry relationship disclosures: NR | Design: Cross-sectional telephone questionnaire, except Spain where in-person interviews were done Base population: Residents of France, Germany, Italy, Spain, Sweden, UK Sampling frame: Stratified random sample to obtain nationally representative respondents from telephone listings (or voter roles in Spain) N sampled: NR N screened: NR N eligible: NR N respondents: Total: 16,776 Women: 9,728 Age, %: 40–44: 17.4 45–49: 14.8 50–54: 13.2 55–59: 12.2 60–64: 11.1 65–69: 10.9 70–74: 8.9 ≥ 75: 11.5 Race/ethnicity: NR | Inclusion criteria: • adults • age ≥ 40 Exclusion criteria: • voiding symptoms suggestive of stress incontinence, prostatic obstruction, or urinary tract infection Effective response: NR | Frequency: > 8 voids/day Urgency: “Strong urge to go to toilet with no advance warning; have to hurry to toilet in time to urinate, have to keep running to toilet to urinate” UUI: “unable to get to bathroom in time; have wetting accidents at night when asleep; sudden and uncontrolled loss of urine; leak urine during the day without being able to control it” OAB: Frequency, urgency, and urge urinary incontinence alone or in any combination | Prevalence of OAB, %: 17.4 Prevalence of OAB by age, %: 40–44: 8.7 45–49: 10.6 50–54: 11.9 55–59: 16.9 60–64: 16.9 65–69: 17.5 70–74: 22.1 75+: 31.3 | Overall quality: Poor Internal validity score: 2, − External Validity Score: 3, + Sampling Method Described: + N sampled provided: − N eligible provided: − N included respondents: + Response Rate:^*^ NR Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: + Required frequency defined^*^: −
Author: M⊘ller et al., 2000 Country: Denmark Study period: June 1996 Funding: Coloplast A/S Pharmacia A/S Four Danish foundations Author industry relationship disclosures: NR | Design: Cross sectional mailed questionnaire Base population: Residents of Denmark Sampling frame: Random sampling of Danish Civil Registry System in age and urban vs. rural strata N screened: 4,000 N eligible: NR N respondents:<br>3,204 N included: 2,860 Age, %: 40: 21.5 45: 20.3 50: 20.0 55: 19.2 60: 18.9 Race/ethnicity: NR | Inclusion criteria: • women • age 40, 45, 50, 55, or 60 Exclusion criteria: NR Effective response, %: 71.7 | UUI: Do you leak urine if suddenly you need to void? Urgency: Do you rush to the toilet because of a sudden desire to void? Daytime frequency: Number of episodes exceeds 10 voids daily.^*^ | Prevalence UUI, weekly or more, %: 7.2 (95% CI: 6.2,8.2) Prevalence of urgency, weekly or more, %: 7.1 (95% CI: 6.1,8.1) Prevalence of daytime frequency, %: 3.6 (95% CI: 2.9,4.3) | Overall quality: Fair Internal validity score: 4, + External Validity Score: 3, + Sampling Method Described: + N sampled provided: + N eligible provided: − N included respondents: + Response Rate:^*^ 71.7 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: Required frequency defined^*^: −
Author: Muller, 2005 Country: US Study period: October 2000 to December 2000 Funding: Pfizer Author industry relationship disclosures: NR | Design: Cross sectional administered questionnaire (NS) Base population: US population Sampling frame: Unspecified sampling of shoppers in retail malls of 20 major urban areas N sampled: NR N screened: NR N eligible: NR N respondents: NR N included: Total: 1,001 Women: NR Age: NR Race/ethnicity: NR | Inclusion criteria: • adults • age 30 to 70 • community dwelling Exclusion criteria: NR Effective response: NR | Definitions: NR | Prevalence of “sudden urge to urinate”, %: 13 Prevalence of “both urge and leakage”, %: 22 | Overall quality: Poor Internal validity score: 1, − External Validity Score: 1,− Sampling Method Described:+ N sampled provided: − N eligible provided: − N included respondents: − Response Rate:^*^ NR Inclusion (Exclusion) Specified: + Age of population described: − Operational definition provided^*^: − Required frequency defined^*^: −
Author: Nuotio et al., 2002 Country: Finland Study period: 1979 to 1989 Funding: Medical Research Fund of Tampere University Hospital, the Academy of Finland, and the Uulo Arhio Foundation Author industry relationship disclosures: NR | Design: Cross-sectional administered questionnaire with similar follow-up questionnaire 10 years later Base population: Elderly residents of Tampere, Finland Sampling frame: Age and gender stratified random sample; part of the European Longitudinal Study on Aging (ELSA) N sampled: 1,494 N screened: NR N eligible: Baseline: 1,309 Follow-up: 518 N included:<br>Total: 1,052 Women: 528 Follow-up: 435 Women: 260 Age, mean:^ 73.2 Race/ethnicity:<br>NR | Inclusion criteria: • Adults • Age ≥ 60 Exclusion criteria: NR Effective response, %: Baseline: 82 Follow-up: 84 | Urgency: “Do you ever have trouble getting to the lavatory in time?” UUI: Urgency and urinary leakage, regardless of the frequency of urine loss | Prevalence of urgency, %: 8 Prevalence of UUI, %: 6 | Overall quality: Fair Internal validity score: 4, + External Validity Score: 4, ++ Sampling Method Described: + N sampled provided: + N eligible provided: − N included respondents: + Response Rate:^*^ 82 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: + Required frequency defined^*^:
Author: Nygaard and Lemke, 1996 Country: US Study period: 1981 to 1988 Funding: NIH Author industry relationship disclosures: NR | Design: Repeated measures, in-person interviews Base population: Residents of two counties in rural Iowa Sampling frame: Age stratified random sample of women with address on record N sampled: NR N screened: NA N eligible: NR N respondents: 2025 Age, %: 65–69: 25.6 70–74: 25.9 75–79: 23.0 80–84: 15.9 85–89: 7.5 ≥ 90: 2.1 Race/ethnicity, %: Non-Hispanic white: 61.7 Hispanic: 19.2 Black: 9.6 Asian-Pacific Islander: 8.2 Other/unknown: 1.3 BMI, mean: 25.4 | Inclusion criteria: • women • age ≥ 65 • living in community Exclusion criteria: NR Effective response, %: 80 | UUI: “How often do you have difficulty holding your urine until you can get to a toilet?” For prevalence, incidence, and remission never and hardly ever = negative response | 3-year incidence of UUI (first follow-up), %: 20.4 3-year remission of UUI (first follow-up), %: 31.7 3-year incidence of UUI (second follow-up), %: 24.0^*^ 3-year remission of UUI (second follow-up), %: 34.9^*^ Baseline prevalence of UUI, %: Total ever: 55 Positive response: 36.3 Baseline prevalence of UUI by how often, %: Hardly ever: 18.6 Some of the time: 27.8 Most of the time: 6.7 All of the time: 1.6 | Overall quality: Fair Internal validity score: 3, + External Validity Score: 4, ++ Sampling Method Described: + N sampled provided: − N eligible provided: − N included respondents: + Response Rate:^*^ 80 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: + Required frequency defined^*^: +
Author: Odeyemi et al., 2006 Country: UK Study period: 1987 to 2004 Funding: Allergan Author industry relationship disclosures: 1 of 6: Allergan (1) | Design: Healthcare database Base population: Residents of the UK receiving care in one of 350 general practices selected to be representative of the National Health Service Sampling frame: General Practice Research Database (4.6% representative sample with longitudinal data) N sampled: NR N screened: NA N eligible: 68,910 Age: NR for total N Race/ethnicity: NR for total N | Inclusion criteria: • adults • in GPRD sample Exclusion criteria: UTI within two weeks before or after visit meeting OAB criteria, renal dysfunction, diuretics use Effective response: NR | OAB-related symptoms: Oxford Medical Index System and Read Clinical Classification codes for urgency, frequency, urge, urgency incontinence, nocturia, unstable bladder or irritable bladder | Annual incidence of OAB-related symptoms (95% CI): 2.60/1,000 (2.57, 2.63) Prevalence of OAB-related symptoms:<br>3.64/1,000 | Overall quality: Fair Internal validity score: (+) External Validity Score: 2, − Sampling Method Described: + N sampled provided: NA N eligible provided: NA N included respondents: NA Response Rate:* NA Inclusion (Exclusion) Specified: + Age of population described: − Operational definition provided*: + Required frequency defined*: −
Author: Perry et al., 2000 Country: UK Study period: October 1996 to June 1997 Funding: Medical Research Council Author industry relationship disclosures: NR | Design: Cross-sectional mailed questionnaire Base population: Patients registered in any of 108 general practices in Leicestershire Sampling frame: Random sample Leicestershire Health Authority registry N sampled: 15,904 N screened: NR N eligible: Total: 14,600 Women: 7,659 N respondents: Total: 10,226 Women: NR N included: Total: 10,116 Women: 5,544 Age, %:^ 40–49: 25.1 50–59: 24.8 60–69: 21.8 70–79: 17.9 ≥80: 10.4 Race/ethnicity: NR | Inclusion criteria: • adults • age ≥ 40 • community dwelling Exclusion criteria: NR Effective response, %:^ 72.4 | Incontinence: Loss of urine several times a month or more Urgency: Experienced an overwhelming urge to pass urine or had difficulty holding urine most of the time or overwhelming Frequency: Voiding hourly or more often | Prevalence of urgency, %: 8.8 Prevalence of frequency, %: 9.1 | Overall quality: Good Internal validity score: 5, ++ External Validity Score: 4, ++ Sampling Method Described: + N sampled provided: + N eligible provided: + N included respondents: + Response Rate:* 72.4 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided*: + Required frequency defined*: +
Author: Rohr et al., 2004 Country: Denmark Study period: NR Funding: NR Author industry relationship disclosures: NR | Design: Cross-sectional telephone questionnaire Base population: Female residents of central Odense Sampling frame: Central Person Register listing of residents in postal district 5000 N sampled: 498 N screened: 498 N eligible: 421 N respondents: 223 N included: 223 Age, median (range): 82 (75, 96) Race/ethnicity: NR | Inclusion criteria: • women • age ≥ 70 Exclusion criteria: • need for proxy respondent Effective response, %: 53 | UUI: Such a strong urge that it was impossible to get to the toilet in time SUI: Involuntary loss of urine in connection with physical exertion in the past month MUI: Both UUI and SUI | Prevalence of UUI, % (95% CI): 16 (10.9, 20.5) Prevalence of MUI, % (95% CI): 13 (8.2, 16.9) | Overall quality: Good Internal validity score: 5, ++ External Validity Score: 4, ++ Sampling Method Described: + N sampled provided: + N eligible provided: + N included respondents: + Response Rate:* 53 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided*: + Required frequency defined*: +
Author: Schulman et al., 1997 Country: Belgium Study period: November 1994 to February 1995 Funding: NR Author industry relationship disclosures: 1 of 3 Marrion Merrell Dow (1) | Design: Cross sectional written questionnaire in home Base population: Residents of Belgium Sampling frame: Two stage, random sampling, stratified by region, gender, age, and profession for nationally representative sample. N screened: 8,000 N eligible: NR N respondents: 5,920 N included: Total: 5,269 Women: 2,770 Age, %: 30–34: 13.3 35–49: 34.0 50–64: 28.0 ≥ 65: 24.7 Race/ethnicity: NR | Inclusion criteria: • adults • age 30 and older • community dwelling Exclusion criteria: NR Effective response, %: NR | UUI: Arriving too late at the toilet | Prevalence of UUI, %: 2.7 | Overall quality: Poor Internal validity score: 3, − External Validity Score: 2, − Sampling Method Described: + N sampled provided: + N eligible provided: − N included respondents: + Response Rate:* NR Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided*: − Required frequency defined*: −
Author: Shakhatreh, 2005 Country: Jordan Study period: July 2003 Funding: NR Author industry relationship disclosures: NR | Design: Cross-sectional administered questionnaire Base population: Female residents of Southern Jordan in this age group Sampling frame: 68 census blocks selected from among 228 to achieve representative sample; household and then individuals randomly selected within blocks N sampled: Households: 810 N screened: NR N eligible: Women: 190^*^ N respondents: 182 N included: 182 Age, %: 50–54: 38.9 55–59: 23.9 60–65: 37.2 Race/ethnicity: NR BMI kg/m^2^, %: 18.5–24: 20 25–29: 32 ≥ 30: 48 Parity, %: 95.8 | Inclusion criteria: • women • age 50 to 65 • community dwelling Exclusion criteria: NR Effective response, %: 96^*^ | UUI: Inability to postpone urination with strong urge to void SUI: Involuntary leakage of urine on exertion as in coughing, sneezing, laughing, bending over, or with exercise as in jumping MUI: Combination of UUI and SUI | Prevalence of UUI, %: 26.4 Prevalence of MUI, %: 18.1 | Overall quality: Fair Internal validity score: 5, ++ External Validity Score: 3, + Sampling Method Described:+ N sampled provided: + N eligible provided: + N included respondents: + Response Rate:^*^ 96 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: + Required frequency defined^*^: −
Author: Simeonova et al., 1999 Country: Sweden Study period: NR Funding: NR Author industry relationship disclosures: NR | Design: Cross-sectional mailed questionnaire Base population: Female residents of the Central [primary care] District of Götenberg Sampling frame: Every fourth female resident (other detail NR) N sampled: 2,911 N screened: NR N eligible: NR N respondents: 2,248 N included: 2,176 Age, %: 20–29: 22.0 30–39: 18.2 40–49: 14.8 50–59: 12.6 60–69: 10.2 70–79: 12.0 ≥ 80: 10.2 Race/ethnicity: NR | Inclusion criteria: • women • age ≥ 20 Exclusion criteria: NR Effective response, %: 74.8 | Incontinence: involuntary loss of urine at least 1x/wk, considered by women to be hygienic or social problem UUI: incontinence preceded by urge to void or uncontrollable voiding with little or no warning SUI: Incontinence precipitated by coughing, sneezing, or physical exertion Mixed: Both UUI and SUI | Prevalence of UUI, %: 5.1 Prevalence of UUI by age, %: 20–29: 0.8 30–39: 1.5 40–49: 4.4 50–59: 4.9 60–69: 7.7 70–79: 10.0 ≥ 80: 13.7 P < 0.01 for increase with age Prevalence of MUI, %: 3.9 Prevalence of MUI by age, %: 20–29: 1.1 30–39: 1.5 40–49: 2.5 50–59: 4.9 60–69: 5.5 70–79: 6.7 ≥ 80: 10.0 P < 0.01 for increase with age | Overall quality: Fair Internal validity score: 4, + External Validity Score: 4, ++ Sampling Method Described: + N sampled provided: + N eligible provided: − N included respondents: + Response Rate:^*^ 74.8 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: + Required frequency defined^*^: +
Author: Siracusano et al., 2003 Country: Italy Study period: NR Funding: Associazione Progetto Continenza Author industry relationship disclosures: NR | Design: Cross-sectional mailed questionnaire Base population: Female residents of Trieste Sampling frame: NR N sampled: 10,000 N screened: NR N eligible: NR N respondents: 3,557 N included: 2,900 Age: NR for respondents Race/ethnicity: NR | Inclusion criteria: • women • age 18 to 49 Exclusion criteria: NR Effective response, %: 29 | UUI: NR | Prevalence of UUI, %: 8.7^*^ | Overall quality: Poor Internal validity score: 2, − External Validity Score: 1, − Sampling Method Described: − N sampled provided: + N eligible provided: − N included respondents: + Response Rate:^*^ 29% Inclusion (Exclusion) Specified: + Age of population described: − Operational definition provided^*^: − Required frequency defined^*^: −
Author: Song et al., 2005 Zhang et al., 2005 Zhang et al., 2006^*^ Country: China Study period: April 2002 Funding: NR Author industry relationship disclosures: NR | Design: Cross-sectional mailed questionnaire (BFLUTS) Base population: Residents of Fuzhou, China Sampling frame: Random sample (3%) of national census records for the city N sampled: 6,066 N screened: NA N eligible: 4,745 N respondents: 4,684 Age, mean ± SD: 40.0 ± 11.1 Race/ethnicity: Han Chinese: 100 BMI, mean ± SD: 21.9 ± 3.0 Vaginally Parous, %: 79.8 | Inclusion criteria: • women • age ≥ 20 Exclusion criteria: NR Effective response, %: 77.2 | Incontinence: Any involuntary loss of urine in last month UUI: incontinence preceded by a sudden urge to void or uncontrollable voiding with little or no warning MUI: Symptoms of stress and urge incontinence OAB: OAB-wet or OAB- dry OAB-wet^*^: Urge incontinence with any combination of at least one of the following: urgency, frequency, nocturia, or mixed incontinence OAB-dry^*^: Urgency with either or both frequency and nocturia Frequency: ≥ 8 voids a day | Prevalence of UUI, %: 10.0 Prevalence of MUI, %: 7.7 UUI and MUI Prevalence increases with age P<0.01 Prevalence of OAB-wet^*^, %: 5.6 Prevalence of OAB-dry^*^, %: 2.4 Overall prevalence of OAB, %: 8.0 Prevalence of urgency, %: 10.2 Prevalence of frequency, %: 16.4 | Overall quality: Good Internal validity score: 5, ++ External Validity Score: 4, ++ Sampling Method Described: + N sampled provided: + N eligible provided: + N included respondents: + Response Rate:^*^ 77.2 Inclusion (Exclusion) Specified: + Age of population described:+ Operational definition provided^*^: + Required frequency defined^*^: +
Author: Stewart et al., 2003 Wagner et al., 2002 Country: US Study period: November 2000 to January 2001 Funding: Pharmacia Author industry relationship disclosures: 2 of 8 Pharmacia (2) | Design: Cross sectional telephone questionnaire Base population: US adults who are English speaking Sampling frame: Nationwide random sample by telephone to achieve representative sample by age, sex, and region N sampled: 17,231 N screened: 11,740 N eligible: 6,201 N respondents: 6,201 N included: Total: 5,204 Women: 2,735 Age, %:^ < 25: 11.2 25–34: 15.3 35–44: 22.2 45–54: 16.5 55–64: 14.1 65–75: 11.1 > 75: 8.6 Race/ethnicity, %:^ White: 81.7 Black: 9.1 Hispanic: 4.2 Other: 3.8 BMI:^ < 22.0: 25.3 22.0–23.9: 15.7 24.0–25.9: 15.9 26.0–29.9: 19.3 ≥ 30: 23.8 | Inclusion criteria: • adults • age 18 or older • English speaking • residential phone • most recent birthday among eligibles Exclusion criteria: NR Effective response, %: 83.9 | OAB-wet: Per ICS 2002 OAB-dry: Per ICS 2002 | Prevalence of OAB-wet, %: 9.3 Prevalence of OAB-dry, %: 7.6 | Overall quality: Fair Internal validity score: 5, ++ External Validity Score: 3, + Sampling Method Described: + N sampled provided: + N eligible provided: + N included respondents: + Response Rate:^*^ 83.9 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: + Required frequency defined^*^: −
Author: Teloken et al., 2006 Country: Brazil Study period: November 2003 to August 2004 Funding: NR Author industry relationship disclosures: NR | Design: Cross sectional, written questionnaire (King’s Health Questionnaire) Base population: Residents of Porto Alegre, Brazil Sampling frame: NR (“population based”) N screened: NR N eligible: NR N respondents: 913 N included: Total: 848 Women: 449 Age, %: < 25: 59.3 26–35: 21.4 36–45: 13.2 46–55: 6.1 Race/ethnicity, %: White: 90.8 Black: 3.9 Other: 5.3 Parity, %:^ 39.9 | Inclusion criteria: • individuals • ages 15 to 55 Exclusion criteria: • current pregnancy • UTI • Diabetes • SUI • diuretic use • urinary tract or gynecologic cancer • renal stones • previous urogenital tract surgery Effective response, %: NR | OAB: Per ICS 2002 | Prevalence of OAB, %: 23.2 | Overall quality: Poor Internal validity score: 1, − External Validity Score: 2, − Sampling Method Described: − N sampled provided: − N eligible provided: − N included respondents: + Response Rate:^*^ NR Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: + Required frequency defined^*^: −
Author: Tikkinen et al., 2008 Country: Finland Study period: November 2003 to February 2004 Funding: Competitive Research Funding of the Pirkanmaa Hospital District; Pfizer Author industry relationship disclosures: 1 of 6 Astellas (1) Orion (1) | Design: Cross-sectional mailed questionnaire (DAN-PSS; AUA- SI) Base population: Women in Finland Sampling frame: Random sample with over-sampling in younger age strata from Finish Population Registry to achieve representative sample with good precision of estimates for all ages N sampled: 3,000 N screened: NR N eligible: 2,989 N respondents: 2,002 N included: 1,728 Age, mean ± SD: 42.3 ± 15.6 Race/ethnicity: NR Parity, %: 64 | Inclusion criteria: • women • age 18 to 79 Exclusion criteria: • pregnant or postpartum women • those reporting current UTI Effective response, %: 57.6 | Urgency: An imperative (strong) urge to urinate, often or always | Age- standardized prevalence of urgency, % (95% CI): 10.2 (8.5, 11.9) | Overall quality: Good Internal validity score: 5, ++ External Validity Score: 4, ++ Sampling Method Described: + N sampled provided: + N eligible provided: + N included respondents: + Response Rate:^*^ 57.6 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: + Required frequency defined^*^: +
Author: Danforth et al., 2007^*^ Townsend et al., 2008 Country: US Study period: Baseline 2000 Follow-up 2002 Funding: NIH Author industry relationship disclosures: None | Design: Repeated measures mailed questionnaires at two time points, with supplement to some individuals with incident 1x/wk incontinence at follow-up Base population: Nurses Health Study (NHS) participants Sampling frame: Members of the NHS cohort N sampled/screened: 121,700 Supplement: 1,939 N respondents: 77,696 Supplement: 1,753 N eligible: 35,754 Supplement: 1,601 Age, mean: 65.3 Race/ethnicity: White: 96.5 Black: 1.6 Hispanic: 0.9 Asian: 0.8 Other: 0.2 BMI kg/m^2^, %: < 21: 12.6 21–24: 36.3 25–29: 33.9 ≥ 30: 17.1 Parity, %: 94.0 | Inclusion criteria: • women • NHS participants returning both baseline and follow-up • community dwelling Exclusion criteria: • missing data on BMI or UI • prevalent UI 1x/mo at baseline • history of major neurologic conditions • significant functional limitations Effective response, %: 46.0 Supplement: 82.6 | Frequent incontinence: Leaking ≥ 1x/wk UUI: Frequent incontinence with a sudden feeling of bladder fullness or when a toilet was inaccessible SUI: Frequent incontinence with coughing or sneezing, lifting things, laughing, or doing exercise MUI: Reporting UUI and SUI symptoms equally | 2-year incidence of UUI, %:^**^ 1.4 2-year incidence of MUI, %:^**^ 1.9 | Overall quality: Fair Internal validity score: 3, + External Validity Score: 4, ++ Sampling Method Described: + N sampled provided: + N eligible provided: + N included respondents: − Response Rate:^*^ 46 Inclusion (Exclusion) Specified: + Age of population described:+ Operational definition provided^*^: + Required frequency defined^*^: +
Author: Townsend et al., 2007 Country: US Study period: Baseline 2001 Follow-up 2003 Funding: NIH Author industry relationship disclosures: NR | Design: Repeated measures mailed questionnaires at two time points, with supplemental questionnaire if ≥ 1x/wk incontinence at follow-up Base population: Nurses Health Study (NHS) participants Sampling frame: Members of the NHSII cohort N sampled/screened: 115,713 N respondents: Baseline: 85,994 Follow-up: 70,712 N eligible: Total: 64,650 Age, mean: 46.4 Age, %: 36–40: 13.2 41–45: 29.1 46–50: 34.8 51–55: 22.9 Race/ethnicity: “Largely Caucasian” BMI kg/m^2^, %: ≥ 25: 50.3 Parity, %: 79.0 | Inclusion criteria: • women • age 35 to 54 at baseline • NHS participants returning both baseline and follow-up Exclusion criteria: • missing data • unclear continence status at baseline Response, %: Baseline: 74 Follow-up: 61 Effective response, %: Total: 57 | Incontinence: “During last 12 months, how often have you leaked or lost control of your urine?” (required ≥ 1x/wk) UUI: Predominance of urge symptoms in the Medical Epidemiological and Social Aspects of Aging questionnaire, per Diokno (1995) SUI: Predominance of stress symptoms MUI: Equal predominance of UUI and SUI symptoms | 2-year incidence of UUI, %: 0.4 2-year incidence of UUI by age, %: 36–40: 0.4 41–45: 0.4 46–50: 0.5 51–55: 0.4 2-year incidence of MUI, %: 0.6 2-year incidence of MUI by age, %: 36–40: 0.3 41–45: 0.6 46–50: 0.7 51–55: 0.9 | Overall quality: Fair Internal validity score: 5, ++ External Validity Score: 4, ++ Sampling Method Described: + N sampled provided: + N eligible provided: + N included respondents: + Response Rate:^*^ 61 Inclusion (Exclusion) Specified: + Age of population described:+ Operational definition provided^*^: + Required frequency defined^*^: +
Author: Tseng et al., 2000 Country: Taiwan Study period: March 1997 to April 1997 Funding: NR Author industry relationship disclosures: NR | Design: Cross-sectional administered questionnaire Base population:<br>Residents of Tungkang Town Sampling frame:<br>Random sample stratified to obtain age and gender representation by city region N sampled: NR N screened: NR N eligible: NR N respondents: NR N included: Total: 504 Women: 256 Age, %: 65–70: 43.1 71–75: 28.1 76–80: 18.4 > 80: 12.1 Race/ethnicity: NR BMI, %: “Overweight”: 47.3^*^ | Inclusion criteria: • adults • age ≥ 65 Exclusion criteria: NR Effective response, %: 80 (per authors cannot calculate) | UI: “ever experienced inappropriate loss of urine” UUI: Because of inability to delay voiding following micturition urge SUI: Loss associated with physical exertion (coughing, sneezing, lifting, or other physical activity) MUI: Features of UUI and SUI | Prevalence of UUI, %: 6.6 Prevalence of MUI, %: 6.3 | Overall quality: Poor Internal validity score: 2, − External Validity Score: 4, ++ Sampling Method Described: + N sampled provided: − N eligible provided: − N included respondents: + Response Rate:^*^ NR Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: + Required frequency defined^*^: +
Author: Ueda et al., 2000 Country: Japan Study period: NR Funding: LACADIA Health and Welfare Foundation; Social Department Foundation for Senior Citizens Author industry relationship disclosures: NR | Design: Cross-sectional mailed questionnaire Base population: Residents of Shiga Prefecture Sampling frame: Random sample of individuals in seven towns N sampled: 3,500 N screened: NR N eligible: NR N respondents: 1,836 N included: Total: 1,786 Women: 968 Age, %:^ 40–49: 26.4 50–59: 28.8 60–69: 29.4 ≥ 70: 15.4 Race/ethnicity:<br>NR BMI: NR | Inclusion criteria: • adults • age 40 to 80 • community-dwelling Exclusion criteria: NR Effective response, %: 51.0 | Incontinence: involuntary loss of urine within prior year UUI: Often have difficulty holding urine until able to get to toilet SUI: Leak when cough, sneeze, or laugh? MUI: Both UUI and SUI | Prevalence of UUI, %: 6.9 Prevalence of UUI by age, %: 40–49: 5.1 50–59: 4.3 60–69: 8.8 ≥ 70: 11.4 Prevalence of MUI, %: 12.9 Prevalence of MUI by age, %: 40–49: 14.5 50–59: 14.3 60–69: 6.3 ≥ 70: 20.1 | Overall quality: Fair Internal validity score: 4, + External Validity Score: 4, ++ Sampling Method Described: + N sampled provided: + N eligible provided: − N included respondents: + Response Rate:^*^ 51 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: + Required frequency defined^*^: +
Author: van der Vaart et al., 2002 Country: Netherlands Study period: 1999 Funding: NR Author industry relationship disclosures: NR | Design: Cross-sectional mailed questionnaire(UDI) Base population:<br>Female residents of the Central Netherlands Sampling frame:<br>Random sample of women from the population registry office of a suburban area N sampled: 1,393 N screened: NR N eligible: NR N respondents: 1,029 N included: 933 Age, mean ± SD: 34.2 ± 3.2 Race/ethnicity: NR BMI, mean ± SD: 23.6 ± 4.2 | Inclusion criteria: • women • age 20 to 45 Exclusion criteria: NR Effective response, %: 67 | UUI: Urine loss related to feeling of urgency OAB: Per ICS Urgency: Per ICS Frequency: Per ICS | Prevalence of UUI, %: 15.3 Prevalence of OAB, %: 11.9 Prevalence of urgency, %: 45.4 Prevalence of frequency, %: 34.0 | Overall quality: Fair Internal validity score: 4, + External Validity Score: 3, + Sampling Method Described: + N sampled provided: + N eligible provided: − N included respondents: + Response Rate:^*^ 67% Inclusion (Exclusion) Specified: + Age of population described:+ Operational definition provided^*^: + Required frequency defined^*^: −
Author: Waetjen et al., 2007 Country: US Study period: 1995 to 2001 Funding: NIH, Univ. of California Davis Health Systems Research Award Author industry relationship disclosures: None | Design: Repeated measures administered questionnaire and follow-up visits Base population: Women in six states near seven urban study centers Sampling frame: Random digit dialing, snowballing, and list sampling based on study center N sampled: 16,065 N screened: 16,065 N eligible: NR N respondents: 16.065 baseline 3,302 included in follow-up based on per center quotas Age, mean ± SD: 45.8 ± 2.7 Race/ethnicity, %: Caucasian: 47.0 Black: 28.3 Chinese: 7.6 Japanese: 8.5 Hispanic: 8.7 BMI, mean ± SD: 28.2 ± 7.2 Parity, mean ± SD: 2.0 ± 1.4 | Inclusion criteria: • women • age 42 to 52 • self-identified as member of one of five race/ethnic groups Exclusion criteria: • inability to speak English, Spanish, Japanese, or Cantonese • no menstrual period in prior 3 months • hysterectomy and/or oophorectomy prior to study • current use of hormones including birth control pills Effective response, %: NR | UUI: at least monthly leakage when “urge to void and can’t reach the toilet fast enough.” SUI: at least monthly leakage “with coughing, laughing, sneezing, jogging, jumping, or picking up an object from the floor.” MUI: Affirmative answers to both UUI and SUI at least monthly | 5-year incidence of UUI, %: 15.9 5-year incidence of MUI, %: 11.9 Baseline prevalence of UUI, %: 7.6 Baseline prevalence of MUI, %: 12.4 | Overall quality: Fair Internal validity score: 3, − External Validity Score: 3, ++ Sampling Method Described: + N sampled provided: + N eligible provided: − N included respondents: + Response Rate:^*^ NR Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: + Required frequency defined^*^: +
Author: Wesnes et al., 2007 Country: Norway Study period: 1999 to 2006 Funding: Research Council of Norway Author industry relationship disclosures: NR | Design: Cross-sectional mailed questionnaire Base population: Pregnant women in Norway Sampling frame: Women receiving prenatal care in one of 52 maternity units N screened: NR N eligible: NR N respondents: 46,262 N included: 43,279 Age, mean (range): 29.5 (14, 47) Race/ethnicity: NR Pre-pregnancy BMI, mean (range): 24.1 (13, 59) Parity, %: 53.8 | Inclusion criteria: • pregnant women • read and write Norwegian • completion of questionnaire by 30-week visit Exclusion criteria: • participated in prior pregnancy Effective response, %: 45 | UUI: Per ICS 2002 MUI: Per ICS 2002 | Prevalence of UUI, before pregnancy, %: 3.8 Prevalence of UUI during pregnancy, %: 4.8 Prevalence of MUI, before pregnancy, %: 5.5 Prevalence of MUI during pregnancy, %: 16.4 | Overall quality: Fair Internal validity score: 3, + External Validity Score: 3, + Sampling Method Described: + N sampled provided: − N eligible provided: − N included respondents: + Response Rate:^*^ 45 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: + Required frequency defined^*^: −
Author: Yarnell et al., 1981 Country: UK Study period: NR Funding: NR Author industry relationship disclosures: NR | Design: Cross-sectional administered questionnaire Base population: Female residents of South Wales Sampling frame: Random sample of electoral role from base population of 38,000 N sampled: 1,140 N screened: NR N eligible: 1,060 N respondents: 1,022 N included: 1,000 Age, %: 17–24: 12 23–34: 21 35–44: 15 45–54: 19 55–64: 15 65–74: 11 ≥ 75: 7 Race/ethnicity: NR BMI: NR | Inclusion criteria: • women • age ≥ 18 Exclusion criteria: NR Effective response, %: 94.3 | UUI: Ever (12 months) have to rush to the toilet to pass water and ever loose water before reaching toilet SUI: Ever (12 months) loose urine when you cough, laugh, sneeze, etc. MUI: Both UUI and MUI | Prevalence of UUI, %: 9.2 Prevalence of UUI by age, %: 17–24: 9 23–34: 5 35–44: 10 45–54: 9 55–64: 10 65–74:13 ≥75: 14 Prevalence of MUI, %: 13.5 Prevalence of MUI by age, %: 17–24: 4 23–34: 8 35–44: 16 45–54: 16 55–64: 15 65–74: 13 ≥ 75: 28 | Overall quality: Good Internal validity score: 5, ++ External Validity Score: 4, ++ Sampling Method Described: + N sampled provided: + N eligible provided: + N included respondents: + Response Rate:^*^ 94.3 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: + Required frequency defined^*^: +
Author: Yu et al., 2006 Country: Taiwan Study period: February 2003 to February 2005 Funding: NR Author industry relationship disclosures: NR | Design: Cross-sectional administered questionnaire Base population: Residents of Matsu Sampling frame: 100% of residents N sampled: 5,456 N screened: NR N eligible: NR N respondents: 1,921 N included: Total: 1,827 Women: 925 Age, %:^ 30–39: 22.6 40–49: 34.5 50–59: 19.4 60–69: 12.8 70–79: 10.8 Race/ethnicity: NR BMI kg/m^2^, %:^ < 24.0: 70.9 24.0–26.9: 20.5 ≥ 27.0: 8.5 Parity, %: 89.4 | Inclusion criteria: • adults • age ≥ 30 in 2000 Exclusion criteria: NR Effective response, %: 33.5 | UUI: Urine loss associated with an urge to void OAB: Per ICS 2002 | Prevalence of OAB, %: 18.3 Prevalence of OAB by age, %: 30–39: 14.4 40–49: 14.7 50–59: 19.6 60–69: 25.4 70–79: 31.0 P = 0.001 for trend | Overall quality: Fair Internal validity score: 4, + External Validity Score: 3, + Sampling Method Described: + N sampled provided: + N eligible provided: − N included respondents: + Response Rate:^*^ 33.5 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: + Required frequency defined^*^: −
Author: Zhu et al., 2008 Country: China Study period: April 2005 to July 2005 Funding: NR Author industry relationship disclosures: NR | Design: Cross-sectional administered questionnaire (Chinese ICIQ) Base population: Female residents of Beijing Sampling frame: 1.0% of female Beijing residents age ≥ 20 (2000 national census data) N sampled: 5,300 N included: 5,221 Age, mean: 46.4 Race/ethnicity: NR | Inclusion criteria: • Age ≥ 20 Exclusion criteria: NR Effective response, %: 98.5 | Incontinence: Any leakage or involuntary loss of urine within the last month. SUI: A leak or loss of urine caused by sneezing, coughing, exercising, lifting, or physical activity. UUI: An urge to urinate but being unable to reach the toilet before leaking or having a strong sudden urge to go to the toilet to urinate with no advance warning. MUI: Experiencing at least one stress and one urge symptom. | Prevalence of UUI, %: 2.8 Prevalence of UUI by menopausal status, %: Premenopause: 1.9 Menopause: 4.0 Prevalence of MUI, %: 12.4 Prevalence of MUI by menopausal status, %: Premenopause: 6.0 Menopause: 20.4 | Overall quality: Good Internal validity score: 4, + External Validity Score: 4, ++ Sampling Method Described: + N sampled provided: + N eligible provided: + N included respondents: + Response Rate:^*^ 98.5 Inclusion (Exclusion) Specified: + Age of population described: + Operational definition provided^*^: + Required frequency defined^*^: −

* Authors provide the strict definition and term it “meeting the criteria of the ICS” in the publication.

* Initial mailing in October with two reminders sent in four week intervals

^ Data presented for women only; for each type of incontinence severity increased with age.

** Prevalence is calculated by multiplying the prevalence of incontinence by the reported proportion of each type of incontinence

* Baseline was in 1983 and 1984 with one year and two year follow-up from those dates.

* Age range as presented “60–69” however, inclusion says all participants >65 years old?!

** Denominator for total community dwelling in Table 1 = 1120 women, Table 3 = 59 with urgency as “nature of urinary incontinence”

† Groupings may have etiologic or other research utility see publication for details.

* Study also included 151 individuals identified within households sampled

** Prevalence for UUI and MUI is calculated by multiplying the prevalence of the combined UUI and MUI (reported in Table 1) by the relevant proportions from Table 3, e.g. 41.4 * 0.384/(0.384+0.495)=18.2

** 12,200 mailed, 4458 returned, 3962 evaluable = effective response of 3962/12,200 = 32.5%

* Calculated from reported frequencies: 271/2,951 and 389/2,951

* More than 10 voids per day is categorized as “often” (and reported in Table III).

* 3-year incidence and remission in the second follow-up are calculated from those women without UUI at baseline.

* Authors report 96% of eligible women participated and 182 = respondents.

* Urge and mixed incontinence prevalence (overall and by age) computed from proportions of types of incontinence estimated from Figure 3.

* Calculated: 43.5% of 581 women with incontinence had urge incontinence (Table 2) and denominator is 2900.

* Incidence of UUI and MUI from Danforth et al., 2007 is 1.4% and 1.8%, respectively.

** Incidence calculated as incidence of frequent UI (1x/wk) times estimated proportion with each type of UI, e.g. (2,416/35,754)*(342/1,601) = 1.4%

^ Data presented for women only.

Prevalence also reported by age.

Estimates of proportions of population with different types of UI use weights “constructed based on age, race and geographic location to adjust for the oversampling and for survey nonresponse.” Estimates of the prevalence of UUI and MUI are computed by multiplying the overall prevalence of UI (reported at the top of page 1457) by the proportions of types of UI (reported in Table 4 on page 1459). For example, overall prevalence of UUI is 0.265×13.6%=3.6%

3537 was described by authors as 77.8% response rate. Therefore ‘N” whom they considered eligible would be 4546, so effective response rate is 3519/4546 = 77.4%

Prevalence, year 1 incidence and remission are reported by age in Table 2 on page 712; urgency is defined in Table 1, but the threshold is only given for “When you need to pass urine, how strong is the urge usually?”

Note: This is a report from the Executive Director of The National Association for Continence presenting for academic audiences consumer research done as part of pre- or post-marketing research by for profit entities. The Association assisted with formation and scope of questions included in the questionnaire.

The total number of UUI cases is 0.026*5,269=137, of which 55% (see page 317) are women. The prevalence of UUI can then be calculated as 137*0.55/2,770=75/2,770=2.7%

Note: differences between UUI and OAB-wet prevalence result from differences in operational definitions used in Zhang et al., 2006.

Prevalence of urgency by age in Figure 2 (no data).

Mean age and prevalence of UUI and MUI by menopausal status calculated from results reported.

Prevalence of UUI and MUI by age groups in Figure 3 on page 567 (no results reported).

Effective response rate is reported on page 1050, but the number sampled is not reported.

Evidence Table 2 KQ 2 Pharmacologic Treatment of OAB

Study Description | Study Design, Interventions, and Population | Inclusion/ Exclusion Criteria | Symptom Characteristics | Outcomes | Quality Rating
Author: Abrams et al., 1998 Country and setting: UK, Ireland, Sweden, Academic medical center Enrollment period: July 1995 to July 1996 Funding: Pharmacia Upjohn Author industry relationship disclosures: NR | Design: RCT Intervention: Tolterodine vs. Oxybutynin vs. Placebo x 12 wks Groups: G1: Tolterodine 2 mg b.i.d. (dose could be reduced to 1.0 mg b.i.d.) G2: Oxybutynin 5 mg t.i.d. (dose could be reduced to 2.5 mg t.i.d.) G3: Placebo N at enrollment: G1: 118 G2: 118 G3: 57 N at follow-up: G1: 118 G2: 117 G3: 56 Women, n (%): G1: 91 (77.1) G2: 88 ( 74.5) G3: 43 (75.4) Age, mean (range): G1: 55 (19–80) G2: 58 (21–80) G3: 58 (26–78) | Inclusion criteria: • Age ≥ 18 • UDS confirmed bladder overactivity • ≥ 8 voids/day • ≥ 1 episode UUI/ day Exclusion criteria: • SUI • Detrusor hyperreflexia • Hepatic, renal, hematological disorders • Symptomatic or recurrent UTI • BOO • Bladder retraining • Electrical stimulation therapy • Indwelling catheter • CIC • Pregnant/ nursing • Women without reliable BC | Incontinence episodes, n (%): G1: 93 (79) G2: 88 (75) G3: 40 (70) Incontinence episodes/day, mean (range): G1: 2.9 (0.1–24.0) G2: 2.6 (0.1–24.0) G3: 3.3 (0.1–23.5) Voids/day, mean (range): G1: 11.5 (6.3–37.0) G2: 10.7 (5.3–27.7) G3: 11.7 (6.9–34.4) ≥ 8 voids/day, n (%): G1: 112 (95) G2: 109 (92) G3: 53 (93) Voided volume (mL), mean (range): G1: 166 (55–426) G2: 176 (57–423) G3: 157 (59–276) Previous OAB therapy, n (%): G1: 61 (52) G2: 71 (60) G3: 43 (75) | Incontinence episodes/day, mean change ± SD: G1: −1.3 ± 3.2 G2: −1.7 ± 3.1 G3: −0.9 ± 1.5 G1/G3: P = 0.22 G2/G3: P = 0.023 Voids/day, mean change ± SD: G1: −2.7 ± 3.8 G2: −2.3 ± 2.7 G3: −1.6 ± 3.6 G1/G3: P = 0.002 G2/G3: P = 0.068 Voided volume (mL), mean change ± SD: G1: 38 ± 54 G2: 47 ± 58 G3: 6 ± 42 G1/G3: P < 0.001 G2/G3: P < 0.001 Subjective improvement in bladder symptoms, %: G1: 50 G2: 49 G3: 47 Dose reductions, n (%): G1: 9 (8) G2: 38 (32) G3: 1 (2) G2/G1: P < 0.001 G2/G3: P < 0.001 Dry mouth, n (%): G1: 59 (50) G2: 102 (86) G3: 12 (21) G1/G3: P < 0.001 G2/G1: P < 0.001 G2/G3: P < 0.001 Dyspepsia, n (%): G1: 11 (9) G2: 27 (23) G3: 3 (5) Nausea, n (%): G1: 4 (3) G2: 7 (6) G3: 6 (11) Upper respiratory infection, n (%): G1: 12 (10) G2: 3 (3) G3: 8 (14) Adverse events reported, N: G1: 302 G2: 412 G3: 117 Patients with ≥ 1 AE, n (%): G1: 105 (89) G2: 114 (97) G3: 46 (81) G2/G1: P = 0.023 G2/G3: P < 0.001 Discontinued due to AEs, n (%): G1: 10 (8) G2: 20 (17) G3: 1 (2) | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: + Masking: + Pt selection criteria: + Loss to followup: ++ Drop-out rates: - Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Abrams et al., 2006 Country and setting: UK, 8 sites Enrollment period: NR Funding: Pfizer Author industry relationship disclosures: 2 of 6 Pfizer (2) | Design: Crossover RCT Intervention: 8 weeks consisting of 2-week run-in period followed by two-week treatment period, 2 week washout, and additional 2 week treatment. Groups: G1: Propiverine 20 mg qd G2: Propiverine 15 mg t.i.d. G3: Oxybutynin 5 mg t.i.d. G4: Placebo N at enrollment: Total: 77 G1: 38 G2: 42 G3: 41 G4: 24 N at follow-up: Safety Analysis: 77 AUM parameter analysis: 69 Women, n (%)*: 59 (76.6) Age, range: 47–56 Race/ethnicity: NR Weight, range (kg): 74–81 | Inclusion criteria: • Age ≥ 18 • Clinical diagnosis of idiopathic OAB with detrusor overactivity • Two or more of the following during 2-week run-in period: urinary frequency (≥ 7 voids/ day), UUI (≥ 1 episode/week requiring change of clothing or pad), urinary urgency (≥ 7 episodes preceding week) Exclusion criteria: • Hepatic, renal or cardiac abnormalities • SUI • Untreated narrow-angle glaucoma • Urinary or gastric retention • BOO > 40 (Abrams-Griffiths number) • Indwelling catheter • Recent urogenital surgery • Use of investigational drugs in 30 days preceding the study | Duration of OAB since diagnosis (years), range: 5–15 f | IDC number, all activities, mean difference (SE): G2/G1: −1.3 (1.4)* G3/G1: −3.8 (1.4) P ≤ 0.01 G3/G2: −2.6 (1.4)* IDC number, with concurrent symptoms, mean difference (SE): G2/G1: −0.9 (0.7)* G3/G1: −1.7 (0.7) P ≤ 0.05 G3/G2: −0.8 (0.7)* IDC duration (sec), all activities, mean difference (SE): G2/G1: −133.6 (88.0)* G3/G1: −244 (91.3) P ≤ 0.01 G3/G2: −110.4 (88.9)* IDC duration (sec), with concurrent symptoms, mean difference (SE): G2/G1: −54.3 (48.0)* G3/G1: 108.1 (50.0) P ≤ 0.05 G3/G2: 53.7 (49.0)* AUC detrusor pressure vs time (cmH_2_0 * s), all activities, mean difference (SE): G2/G1: −0.1 (0.5)* G3/G1: −0.3 (0.5)* G3/G2: −0.2 (0.5)* AUC detrusor pressure vs. time (cmH_2_0 * s), with concurrent symptoms, mean difference (SE): G2/G1: −0.2 (0.8)* G3/G1: −1.3 (0.8)* G3/G2: −1.1 (0.8)* IDC max amplitude (cmH_2_0), all activities, mean difference (SE): G2/G1: −3.8 (8.2)* G3/G1: −16.8 (8.5)* G3/G2: 12.7 (8.3)* IDC max amplitude (cmH_2_0), with concurrent symptoms, mean difference (SE): G2/G1: −5.0 (7.6)* G3/G1: −15.8 (7.9) P ≤ 0.05 G3/G2: −10.7 (7.7)* Salivary flow rate, mean difference (SE): G2/G1: 0.0 (0.7)* G3/G1: −0.6 (0.1) P < 0.0001 G3/G2: −0.6 (0.1) P < 0.0001 Visual near point, mean difference (SE): G2/G1: 1.6 (1.2)* G3/G1: 0.6 (1.2)* G3/G2: −1.0 (1.2)* Heart rate, mean difference (SE): G2/G1: 2.7 (1.4) P < 0.05 G3/G1: −5.1 (1.4) P < 0.0001 G3/G2: −7.8 (1.4) P < 0.0001 PNN50, mean difference (SE): G2/G1: −3.6 (1.8) P < 0.05 G3/G1: 6.2 (1.8) P < 0.0001 G3/G2: 9.9 (1.8) P < 0.0001 St. George’s index, mean difference (SE): G2/G1: −3.5 (1.9) P < 0.05 G3/G1: 3.4 (1.9) P < 0.05 G3/G2: 6.9 (1.9) P < 0.0001 Dry mouth, n (%): G1: 13 (34) G2: 22 (52) G3: 34 (83) G4: 4 (17) Abnormal vision, n (%): G1: 9 (24) G2: 14 (33) G3: 9 (22) G4: 0 Constipation, n (%): G1: 6 (16) G2: 10 (24) G3: 4 (10) G4: 0 Headache, n (%): G1: 1 (3) G2: 3 (7) G3: 6 (15) G4: 0 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: - Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: ++ Power calculation: - Statistical issues: + EXTERNAL VALIDITY: fair Age: -, NR Baseline OAB status: NR Baseline characteristics: - Length of followup: - Measurement methods: + Measurement reliability: + Intervention description: +
Author: Anderson et al., 1999 Country and setting: US, multi-center Enrollment period: NR Funding: Oros Oxybutynin Study group Alza Corp Author industry relationship disclosures: NR | Design: RCT Intervention: Oxybutynin CR vs. Oxybutynin IR 1 wk washout period prior to initiation of study Groups: G1: Oxybutynin 5, 10, 15, 20, 25, or 30 mg CR qd G2: Oxybutynin 5 mg IR daily to qid N at enrollment: G1: 53 G2: 52 N at follow-up: G1: 46 G2: 47 Age, yrs ± SD: G1: 59.2 ± 10.6 G2: 59.6 ± 10.0 Race/ethnicity: NR Women, N (%): G1: 50 (94) G2: 47 (90) | Inclusion criteria: • Community dwelling • Symptoms of urge incontinence or mixed incontinence with primary urge symptoms • ≥6 episodes UUI/wk when not taking medications • Previous favorable response with oxybutynin Exclusion criteria: • Myasthenia gravis • Narrowing of GI tract • glaucoma • Pregnant/lactating • Positive urine drug screen • Receiving meds other than oxybutynin, hyoscamine, or propantheline which was considered effective in UUI treatment • At risk for complete urinary retention caused by anticholinergic treatment • Prostate surgery in last 9 mos • BOO • PVR>100 | UUI episodes/week, mean ± SD: G1: 27.4 ± 24.0 G2: 23.4 ± 16.3 Total incontinence episodes, mean ± SD: G1: 29.3 ± 24.2 G2: 26.3 ± 18.5 Voids/week, mean ± SD: G1: 48.3 ± 18.4 G2: 51.5 ± 19.4 Voided volume/void (mL), mean ± SD: G1: 134.2 ± 82 G2: 161.2 ± 92 PVR/void (mL), mean ± SD: G1: 15.4 ± 21 G2: 18.0 ± 24 Total bladder volume/void (mL), mean ± SD: G1: 149.7 ± 90 G2: 179.2 ± 95 | UUI episodes/week, mean: G1: 4.8 G2: 3.1 P = 0.6 Total incontinence episodes, mean: G1: 6 G2: 3.8 P = 0.7 Percentage reduction in UUI episodes/week (%): G1: 84 G2: 88 P = 0.7 No UUI episodes/week, %: G1: 52 G2: 51 P = 0.7 Totally continent, %: G1: 41 G2: 41 P = 0.9 Voided volume/void (mL), mean ± SD: G1: 176.6 ± 138 G2: 194.5 ± 152 P = 0.1 PVR/void (mL), mean ± SD: G1: 33.5 ± 77 G2: 36.1 ± 59 P = 0.2 Total bladder volume/void (mL), mean ± SD: G1: 210.1 ± 148 G2: 230.6 ± 176 P = 0.9 ≥1 anticholinergic event, n (%): G1: 46 (87) G2: 49 (94) Dry Mouth, n (%): G1: 36 (68) G2: 45 (87) P = 0.04 Moderate-severe dry mouth, n (%): G1: 13 (25) G2: 24 (46) P = 0.03 Somnolence, n (%): G1: 20 (38) G2: 21 (40) P = 0.8 Blurred vision, n (%): G1: 15 (28) G2: 9 (17) P = 0.3 Constipation, n (%): G1: 16 (30) G2: 16 (31) P = 1.0 Dizziness, n (%): G1: 15 (28) G2: 20 (38) P = 0.3 Impaired urination, n (%): G1: 13 (25) G2: 15 (29) P = 0.7 Nervousness, n (%): G1: 13 (25) G2: 12 (23) P = 1.0 Nausea, n (%): G1: 10 (19) G2: 9 (17) P = 1.0 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: − Masking: + Pt selection criteria: + Loss to followup: ++ Drop-out rates: + Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Anderson et al., 2006 [See evidence table for Diokno et al. 2003] Country and setting: US, Multicenter Enrollment period: NR Funding: NR Author industry relationship disclosures: 1 of 6 ALZA Corp (1) | Design: RCT Intervention: Extended release antimuscarinic medications in women with or without prior antimuscarinic treatment for OAB Groups: G1: Prior antimuscarinic G1a: Oxybutynin ER 10 mg po daily G1b: Tolterodine ER 4mg po daily G2: No prior anticholinergic treatment G2a: Oxybutynin ER 10 mg po daily G2b: Tolterodine ER 4mg po daily Ga: Oxybutynin ER 10 mg po daily Gb: Tolterodine ER 4mg po daily N at enrollment: Total: 790 G1: 373 G1a: 180 G1b: 193 G2: 417 G2a: 211 G2b: 206 N at follow-up, 12 weeks: G1: 341 G1a: 165 G1b: 176 G2: 355 G2a: 174 G2b: 181 Women, %: 100 Age, mean ± SD: G1a: 62.6 ± 12.9 G1b: 62 ± 12.6 G2a: 57.5 ± 13.4 G2b: 58.8 ± 12.4 Race/ethnicity, %: White: G1a: 87 G1b: 88 G2a: 82 G2b: 84 Black: G1a: 7 G1b: 9 G2a: 9 G2b: 8.7 Asian: G1a: 0.6 G1b: 0 G2a: 0 G2b: 1 Hispanic: G1a: 5.6 G1b: 3.1 G2a: 8.1 G2b: 6.3 Other G1a: 0 G1b: 0.5 G2a: 0.9 G2b: 0 | Inclusion criteria: • Women • Age ≥ 18 • Mean of 21–60 UUI episodes per week and mean of ≥ 10 voids per 24 hr Exclusion criteria: NR | UUI episodes/wk, mean ± SD: G1a: 36.8 ± 16.4 G1b: 37.4 ± 14.0 G2a: 37.5 ± 14.0 G2b: 36.2 ± 13.9 Incontinence episodes/wk, mean ± SD: G1a: 41.5 ±19.0 G1b: 43.0 ± 18.0 G2a: 45.0 ±19.4 G2b: 41.9 ± 17.9 Voids/week, mean ± SD: G1a: 92.8 ± 23.7 G1b: 94.6 ± 25.2 G2a: 96.5 ± 27.1 G2b: 97.9 ± 24.2 | UUI episodes/wk, mean ± SD: G1a: 11.4 ± 17.9 G1b: 13.3 ± 15.1 G2a: 10.2 ± 13.7 G2b: 9.3 ± 13.3 G1a/G1b: P = 0.3 UUI episodes/wk, completed wk 12, mean ± SD: G1a: 9.9 ± 14.1 G1b: 12.9 ± 14.9 P = 0.049 No UUI, 12 wk, %: G1a: 25.2 G1b: 16.4 G2a: 29.4 G2b: 26.4 G1a/G1b: P = 0.046 G2a/G2b: P = 0.495 Incontinence episodes/wk, mean ± SD: G1a: 12.7 ± 18.7 G1b: 16.5 ± 19.8 G2a: 11.9 ± 15.1 G2b: 11.3 ± 16.0 G1a/G1b: P = 0.09 for LOCF (P = 0.012 if completed wk 12) G2a/G2b: P = 0.886 Voids/week, mean ± SD: G1a: 68.4 ± 17.2 G1b: 72.8 ± 25.4 G2a: 64.8 ± 22.0 G2b: 69.4 ± 21.3 G1a/G1b: P = 0.05 for LOCF (P = 0.026 wk 12) G2a/G2b: P = 0.035 for LOCF (P = 0.026 wk 12) Dry mouth, % G1a: 32 G1b: 19 G2a: 27.5 G2b: 25.2 G1a/G1b: P = 0.004 G2a/G2b: P = 0.6 Constipation, %: G1a: 7.8 G1b: 5.2 G2a: 5.2 G2b: 10.2 Diarrhea, %: G1a: 7.8 G1b: 5.7 G2a: 8.1 G2b: 6.8 Headache, %: G1a: 4.4 G1b: 5.2 G2a: 6.6 G2b: 6.8 Discontinued due to AE, n (%): G1a: 7 (3.9) G1b: 6 (3.1) G2a: 13 (6.2) G2b: 13 (6.3) Withdrew, %: G1: 3.5 G2: 6.2 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: + Pt selection criteria: + Loss to followup: ++ Drop-out rates: ++ Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Appell, Abrams et al., 2001 Country and setting: Multinational, Multicenter Enrollment period: NR Funding: Pharmacia Author industry relationship disclosures: NR | Design: Open-label extension study (after 12-wk RCT and 1 wk washout) Intervention: Tolterodine 2 mg b.i.d. with option for patients to self-lower their dosage to 1 mg b.i.d. Groups: NA N at enrollment: 854 N at follow-up, n (%): 594 (70) Age, yrs, mean (range): 59.5 (19–89) Race/ethnicity: NR Women, %: 76 Previous drug therapy for OAB, n (%): 472 (55) Previous lower urinary tract surgery, n (%): 291 (34) | Inclusion criteria: • ≥18 years old • Cystometric evidence of detrusor overactivity (phasic detrusor contraction with amplitude 10+ cm H2O) • ≥ 8 voids/day • ≥ 1 urinary incontinence episode/day Exclusion criteria: • SUI • Hepatic or renal disease • Recurrent or symptomatic UTIs • Interstitial cystitis • Hematuria secondary to malignant disease • Contraindication to anti-muscarinic therapy • Serious AE on oxybutynin • Clinically significant voiding difficulty w/treatment of urinary retention • Treatment in 14 days prior to baseline visit • Initiation of antimuscarinic or any drug for UI during study • Electro-stimulation or bladder training • Indwelling or intermittent catheter • Total voided volume >3L/day | Detrusor instability, %: 93.7 UUI episodes, n (%): 724 (85) Symptom duration > 5 yrs, n (%): 412 (48) Urgency, n (%): 841 (98) Severe/very severe problems, n (%): 384 (45) UUI episodes/day, mean (range): 3.5 (0.1–24.0) Voids/day, mean (range): 11.4 (5.3–37.0) Voided volume (mL), mean (range): 159 (25–423) Adverse events at end of 12-wk RCT, n (%): Any: 358 (76) ANS: 203 (43) CNS: 59 (12) GI: 125 (26) Respiratory: 68 (14) Urinary: 50 (11) Dry mouth: 187 (39) UTI: 26 (5) Headache: 49 (10) Constipation: 31 (7) Abdominal pain: 36 (8) URI: 28 (6) | UUI episodes/day, 3 mos, mean (range): 1.3 (0.0–24.0) UUI episodes/day, mean change (95% CI): −2.1 (−2.4, −1.9) P = 0.0001 UUI episodes/day, 3 mos, mean (range): 1.5 (0.0–24.0) UUI episodes/day, mean change (95% CI): −2.0 (−2.2, −1.7) P = 0.0001 UUI episodes/day, median % change: −76 Voids/day, 3 mos, mean (range) 8.8 (2.0–23.4) Voids/day, 3 months, mean change (95% CI): −2.6 (−2.8, −2.3) P = 0.0001 Voids/day, 9 mos, mean (range): 8.9 (1.9–31.6) Voids/day, 9 months, mean change (95% CI): −2.5 (−2.9, −2.4) P = 0.0001 Voids/day, 9 mos, median % change: −22 Voided volume (mL), 3 mos, mean (range): 201 (33–444) Voided volume (mL), 3 mos, mean change (95% CI): 41 (36, 45) P = 0.0001 Voided volume (mL), 9 mos, mean (range): 199 (34–514) Voided volume (mL), 9 mos, mean change (95% CI): 40 (35, 45) P = 0.0001 Voided volume (mL), 9 mos, median % change: 22 Improvement, 9 mos, %: 65 Any adverse event, n (%): 652 (76) ANS, n (%): 268 (31) General, n (%): 219 (26) CNS/PNS, n (%): 82 (10) GI, n (%) 201 (24) Respiratory, n (%): 139 (16) Urinary, n (%): 165 (19) Dry mouth, n (%): 236 (28) Mild dry mouth, %: 19 Moderate dry mouth, %: 7 Severe dry mouth, %: 2 UTI, n (%): 106 (12) Headache, n (%): 57 (7) Constipation, n (%): 57 (7) Abdominal pain, n (%): 50 (6) Upper respiratory tract infection, n (%): 45 (5) Serious adverse events, n: 72 Discontinued due to AE, n (%): 73 (9) Reduced dosage to 1 mg b.i.d., n (%): 108 (13) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Appell, Sand et al., 2001 Country and setting: US, 37 sites Enrollment period: March 2000 to October 2000 Funding: ALZA Corp Author industry relationship disclosures: 12 of 12 ALZA (12) Pharmacia (9) | Design: RCT stratified by UUI severity (mild ≤ 21/wk, or moderate >21/wk) Intervention: Oxybuynin ER vs Tolterodine Groups: G1: Oxybutynin ER 10 mg G2: Tolterodine 4mg (2mg b.i.d.) N at enrollment: G1: 185 G2: 193 N at follow-up: G1: 160 G2: 172 Women, %: G1: 82 G2: 85 Age, mean ± SD: G1: 58.6 ± 13.4 G2: 59.6 ± 13.2 Race/ethnicity, %: White: G1: 87.6 G2: 86.0 Black: G1: 5.4 G2: 6.7 Hispanic: G1: 3.8 G2: 5.2 Asian: G1: 2.2 G2: 1.6 Other: G1: 1.1 G2: 0.5 Follow-up: 12 week | Inclusion criteria: • 7–50 urge urinary incontinence episodes per week • ≥ 10 voids/day • Majority of leakage urge-related Exclusion criteria: • Non-OAB cause for incontinence • Delivered baby < 6 mos prior • PVR >150 mL • Significant medical comorbidities • Decreased hepatic function • Renal impairment • Myasthenia gravis • Gastroparesis • Hematuria • Narrow-angle glaucoma • POP to hymen • Known allergy • Pregnant or lactating | UUI episodes/week, mean ± SD: G1: 25.5 ± 14.6 G2: 24.6 ± 15.1 P = 0.36 Incontinence episodes/week, mean ± SD: G1: 28.4 ± 17.8 G2: 28.0 ± 18.3 P = 0.62 Voids/week, mean ± SD: G1: 92.9 ± 23.0 G2: 91.8 ± 20.0 P = 0.77 Received antimuscarinic med before study, n (%): G1: 75 (40.5) G2: 73 (37.8) | UUI episodes/week, mean ± SD (95% CI): G1: 6.1 ± 9.7 (4.4, 7.3) G2: 7.8 ± 11.1 (6.7, 9.5) P = 0.03 Incontinence episodes/week, mean ± SD (95% CI): G1: 7.1 ± 12.0 (5.2, 8.6) G2: 9.3 ± 13.4 (8.0, 11.3) P = 0.02 Voids/week, mean ± SD (95% CI): G1: 67.1 ± 22.1 (64.6, 70.0) G2: 71.5 ± 20.5 (69.1, 74.2) P = 0.02 Discontinuation due to AE, n (%): G1: 14 (7.6) G2: 15 (7.8) P > 0.99 Dry mouth, n (%): G1: 52 (28.1) G2: 64 (33.2) Constipation, n (%): G1: 13 (7) G2: 12 (6.2) Impaired urination/retention, n (%): G1: 6 (3.2) G2: 6 (3.1) P ≥ 0.99 Blurred vision, n (%): G1: 4 (2.2) G2: 2 (1.0) P = 0.44 Dizziness, n (%): G1: 9 (4.9) G2: 8 (4.1) P = 0.81 Somnolence, n (%): G1: 8 (4.3) G2: 3 (1.6) P = 0.13 Asthenia, n (%): G1: 3 (1.6) G2: 7 (3.6) P = 0.34 Insomnia, n (%): G1: 1 (0.5) G2: 3 (1.6) P = 0.62 Headache, n (%): G1: 15 (8.1) G2: 17 (8.8) P = 0.86 Dyspepsia, n (%): G1: 11 (5.9) G2: 10 (5.2) P = 0.82 Nausea, n (%): G1: 6 (3.2) G2: 3 (1.6) P = 0.33 Vomiting, n (%): G1: 3 (1.6) G2: 3 (1.6) P > 0.99 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Arruda et al., 2008 Country and setting: Brazil, community Enrollment period: August 2001 to September 2005 Funding: NR Author industry relationship disclosures: None | Design: RCT Intervention: Oxybutynin vs. functional electrostimulation vs. pelvic floor training Groups: G1: Oxybutynin 5 mg b.i.d. G2: Ambulatory stimulation applied vaginally G3: Pelvic floor exercises with a therapist and at home N Screened: 81 N at enrollment: G1: 22 G2: 21 G3: 21 N at follow-up: G1: 22 G2: 21 G3: 21 Age, range: 35–80 Race/ethnicity: NR Women, %: 100 Length of follow up: 12 weeks | Inclusion criteria: • Community-dwelling • Dx of OAB and DO • Capable of completing a bladder diary and performing a pelvic muscle floor contraction • For those with MUI, urge was predominant Exclusion criteria: • Hx of psychiatric or neurologic illness • Persistent UTI • Inability to comply with regular follow-up visits • Current pregnancy • Postvoid residual volume > 100 ml • Contraindications to anticholinergic therapy • Cardiac pacemaker • Type III SUI • Uncontrolled metabolic conditions or indwelling catheterization • Using medications including anticholinergic drugs, calcium antagonists, beta agonists, dopamine agonists, striated muscle relaxants or estrogens • Any uterine prolapsed | UUI episodes/week, mean ± SD: G1: 13.8 ± 11.6 G2: 13.5 ± 15.6 G3: 16.4 ± 17.2 Nocturia episodes/week, mean ± SD: G1: 1.7 ± 1.5 G2: 1.9 ± 1.9 G3: 1.4 ± 1.2 Pads/day, mean ± SD: G1: 2.6 ± 2.7 G2: 2.3 ± 2.4 G3: 2.7 ± 1.5 Voids/day, mean ± SD: G1: 7.7 ± 2.6 G2: 8.6 ± 3.4 G3: 6.8 ± 2.2 Residual volume mean mL ± SD: G1: 3.2 ± 6.3 G2: 1.0 ± 2.6 G3: 1.8 ± 3.3 Volume, first desire to void, mean mL ± SD: G1: 117.7 ± 68.9 G2: 102.4 ± 51.1 G3: 86.7 ± 38.9 Maximal cystometric capacity, mean mL ± SD: G1: 410.4 ± 194.1 G2: 350.0 ± 212.9 G3: 424.0 ± 149.0 Involuntary detrusor contraction volume mean mL ± SD: G1: 189.5 ± 114.1 G2: 220.0 ± 127.2 G3: 239.3 ± 163.0 Involuntary detrusor contraction maximal pressure (mm H_2_0): G1: 39.4 ± 26.1 G2: 43.7 ± 22.9 G3: 34.2 ± 19.8 | UUI episodes/week, mean ± SD: G1: 7.0 ± 10.6 G2: 7.9 ± 13.7 G3: 7.8 ± 15.3 G1/BL: P = 0.007 G2/BL: P = 0.039 G3/BL: P = 0.035 Urgency resolved, n (%): G1: 14 (63.6) G2: 11 (52.4) G3: 12 (57.1) P = 0.754 Satisfied, n (%): G1: 17 (77.3) G2: 11 (52.4) G3: 16 (76.2) P = 0.142 Nocturia episodes/week, mean ± SD: G1: 0.9 ± 0.8 G2: 1.2 ± 1.3 G3: 1.0 ± 1.1 G1/BL: P = 0.003 G2/BL: P = 0.036 G3/BL: P = 0.086 Pads/day, mean ± SD: G1: 0.9 ± 1.5 G2: 0.9 ± 1.7 G3: 0.8 ± 1.3 G1/BL: P < 0.001 G2/BL: P = 0.004 G3/BL: P < 0.001 Voids/day, mean ± SD: G1: 6.4 ± 1.6 G2: 7.9 ± 2.3 G3: 7.1 ± 2.1 G1/BL: P = 0.014 G2/BL: P = 0.291 G3/BL: P = 0.441 Residual volume, mean mL ± SD: G1: 4.7 ± 9.4 G2: 1.1 ± 2.5 G3: 2.1 ± 3.5 G1/BL: P = 0.425 G2/BL: P = 0.760 G3/BL: P = 0.297 Volume first desire to void, mean mL ± SD: G1: 157.3 ± 63.8 G2: 123.8 ± 59.0 G3: 137.6 ± 76.7 G1/BL: P = 0.019 G2/BL: P = 0.091 G3/BL: P = 0.017 Maximal cystometric capacity mean mL ± SD: G1: 517.3 ± 191.7 G2: 436.6 ± 178.7 G3: 489.0 ± 141.3 G1/BL: P = 0.001 G2/BL: P = 0.017 G3/BL: P = 0.113 Involuntary detrusor contraction volume (mL): G1: 188.6 ± 183.2 G2: 73.3 ± 112.4 G3: 114.3 ± 154.2 G1/BL: P = 0.986 G2/BL: P = 0.001 G3/BL: P = 0.044 Involuntary detrusor contraction maximal pressure, mm H_2_0 ± SD: G1: 19.6 ± 20.9 G2: 22.4 ± 30.1 G3: 17.2 ± 25.5 G1/BL: P < 0.001 G2/BL: P = 0.002 G3/BL: P = 0.027 Normal urodynamic evaluation, n (%): G1: 8 (36.4) G2: 12 (57.1) G3: 11 (52.4) P = 0.358 Persistent improvement at 1 year: G1: 10/17 G2: 4/11 G3: 9/16 Dry mouth, n (%): G1: 16 (72.7) G2: 0 G3: 0 Difficulty voiding, n (%): G1: 2 (9.1) G2: 0 G3: 0 Dizziness, n (%): G1: 1 (4.5) G2: 0 G3: 0 Blurred vision, n (%): G1: 1 (4.5) G2: 0 G3: 0 Constipation, n (%): G1: 1 (4.5) G2: 0 G3: 0 Dry mouth, n (%): G1: 16 (72.7) G2: 0 G3: 0 Difficulty voiding, n (%): G1: 2 (9.1) G2: 0 G3: 0 Dizziness, n (%): G1: 1 (4.5) G2: 0 G3: 0 Blurred vision, n (%): G1: 1 (4.5) G2: 0 G3: 0 Constipation, n (%): G1: 1 (4.5) G2: 0 G3: 0 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: − Method and blinding: − Pt selection criteria: + Loss to followup: + Drop-out rates: − Power calculation: + Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: + Length of followup: + Measurement methods: − Measurement reliability: − Intervention description: +
Author: Barkin et al., 2004 Country and setting: Canada, Community Enrollment period: NR Funding: Purdue Pharma Author industry relationship disclosures: NR | Design: RCT Intervention: Oxybutynin CR versus Oxybutynin IR 3 week washout period followed by 2 weeks of dose titration plus 4 weeks stable dose period Groups: G1: Oxybutynin CR 15 mg daily Final titration dose, n (%): 5 mg: 3 (6) 10mg: 10 (19) ≥ 15mg: 40 (75) G2: Oxybutynin IR 5 mg t.i.d. Final titration dose, n (%): 5 mg: 6 (15) 10mg: 14 (34) ≥ 15mg: 21 (51) N at enrollment: G1: 65 G2: 60 N at follow-up: G1: 53 G2: 41 Women, n (%): G1: 48 (91) G2: 37 (90) Age, yrs ± SD: G1: 58.0 ± 12.4 G2: 60.6 ± 14.8 Race/ethnicity: NR | Inclusion criteria: •Age ≥ 18 •≥ 7 UUI/week during washout period •≥ 8 voids/day during washout period Exclusion criteria: •PVR> 100mL •Unstable dosage of any drug with anticholinergic or diuretic/antidiuretic side effects •Allergy or previous life threatening side effects with anticholinergic/antispasmodic meds •SUI •Conditions contraindicating anticholinergic therapy •Daily fluid intake > 3 liters •Hepatic/renal disease •IC/painful bladder syndrome •Urinary retention •Hematuria •UTI •Recurrent UTI •Indwelling catheter •Bladder training within 14 days of screening •Drug/alcohol abuse •Untreated psychiatric disease effecting completion of bladder diary •Untreated constipation •BOO •Pregnant or breast feeding •Women using reliable method of birth control | Purdue Urgency Questionnaire, frequency, mean score ± SD: G1: 3.3 ± 1.1 G2: 3.2 ± 0.9 Purdue Urgency Questionnaire, severity, mean score ± SD: G1: 3.8 ± 1.1 G2: 3.7 ± 1.1 Incontinence episodes/week, mean ± SD: G1: 24.3 ± 19.0 G2: 23.0 ± 17.7 Pads/day, mean: G1: 2.3 G2: 2.4 Voids/day, mean ± SD: G1: 11.4 ± 2.9 G2: 11.0 ± 3.1 Voided volume (mL), mean ± SD: G1: 177 ± 77 G2: 221 ± 137 Fluid intake (cups/day), mean: G1: 6.8 G2: 6.6 IIQ, mean score ± SD: G1: 2.6 ± 0.8 G2: 2.3 ± 0.8 UDI, mean score ± SD: G1: 2.6 ± 0.6 G2: 2.5 ± 0.4 | Purdue Urgency Questionnaire, frequency, mean ± SD: G1: 2.3 ± 1.2 G2: 1.9 ± 0.9 G1/G2: P = 0.116 G1/BL: P < 0.001 G2/BL: P < 0.001 Purdue Urgency Questionnaire, severity, mean ± SD: G1: 2.3 ± 1.0 G2: 2.3 ± 1.3 G1/G2: P = 0.255 G1/BL: P < 0.001 G2/BL: P < 0.001 Incontinence episodes/week, mean ± SD: G1: 10.4 ± 18.8 G2: 6.1 ± 8.8 G1/G2: P = 0.404 G1/BL: P < 0.001 G2/BL: P < 0.001 Pads/day, mean: G1: 1.7 G2: 1.9 G1/G2: P = NS G1/BL: P < 0.001 G2/BL: P < 0.001 Voids/day, mean ± SD: G1: 9.6 ± 2.6 G2: 8.6 ± 2.8 G1/G2: P = 0.286 G1/BL: P < 0.001 G2/BL: P < 0.001 Voided volume (mL), mean ± SD: G1: 202 ± 80 G2: 261 ± 119 G1/G2: P = 0.533 G1/BL: P = 0.064 G2/BL: P = 0.077 Fluid intake (cups/day), mean: G1: 7.0 G2: 7.7 G1/G2: P = NS G1/BL: P = NS G2/BL: P = 0.032 IIQ score, mean ± SD: G1: 1.9 ± 1.7 G2: 1.6 ± 0.6 G1/G2: P = NS G1/BL: P < 0.001 G2/BL: P < 0.001 UDI scores, mean ± SD: G1: 2.0 ± 0.6 G2: 1.8 ± 0.5 G1/G2: P = NS G1/BL: P < 0.001 G2/BL: P < 0.001 Dry mouth, overall, n (%): G1: 44 (68) G2: 43 (72) Dry mouth, moderate/severe, n (%): G1: 25 (38) G2: 27 (45) Dry throat, n (%): G1: 23 (35) G2: 24 (40) Dry skin, n (%): G1: 11 (17) G2: 7 (12) Diarrhea, n (%): G1: 9 (14) G2: 3 (5) Headache, n (%): G1: 8 (12) G2: 13 (22) UTI, n (%): G1: 8 (12) G2: 11 (18) Dizziness, n (%): G1: 7 (11) G2: 11 (18) Dyspepsia, n (%): G1: 7 (11) G2: 10 (17) Rhinitis, n (%): G1: 7 (11) G2: 9 (15) Abdominal pain, n (%): G1: 6 (9) G2: 6 (10) Asthenia, n (%): G1: 5 (18) G2: 9 (15) Constipation, n (%): G1: 5 (8) G2: 6 (10) Taste perversion, n (%): G1: 5 (8) G2: 7 (12) Cough increased, n (%): G1: 4 (6) G2: 8 (13) Dysphagia, n (%): G1: 4 (6) G2: 8 (13) Dry eyes, n (%): G1: 2 (3) G2: 9 (15) Nausea, n (%): G1: 3 (5) G2: 10 (17) Discontinued due to AEs, n (%): G1: 11 (17) G2: 12 (20) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: − Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: + Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Bemelmans et al., 2000 Country and setting: Netherlands, Primary Care Enrollment period: May 1995 to September 1997 Funding: Byk Nederland (Distributor Oxybutynin) Author industry relationship disclosures: NR | Design: Prospective case series Intervention: Oxybutynin Run in study with all subjects enrolled in G1 with assessment at 2 wks treatment with diary followed by movement to G2 if effect was unsatisfactory or capable of improvement Tx × 4 more wks followed by voiding diary. Groups: G1: Responders to oxybutynin 2.5 mg t.i.d. G2: Non responders to oxybutynin 2.5 mg t.i.d. increased to xybutynin 5 mg t.i.d. N at enrollment: Total: 416 G1: 320 G2: 96 N at follow-up: 350 Women, N (%): 346 (83.2) Age, mean (range): 61.3 (16.4–91.5) Race/ethnicity: NR | Inclusion criteria: • Complaint of involuntary urine loss • Score of ≥ 14 on symptom score questionnaire indicating UUI (determined by unvalidated questionnaire) Exclusion criteria: • Age ≤ 15 • Concurrent use of bladder medication • Urinary retention • Hematuria • UTI • SUI | Incontinence episodes/day, mean ± SD: G1: 5.6 ± 3.5 G2: 7.2 ± 3.9 Voids/day, mean ± SD: G1: 9.6 ± 3.5 G2: 11.1 ± 3.9 | Incontinence episodes/day, mean ± SD: G1: 1.5 ± 1.5 G2: 2.3 ± 2.3 G1/BL: P < 0.001 G2/BL: P < 0.001 Voids/day, mean ± SD: G1: 5.8 ± 2.3 G2: 6.8 ± 2.9 G1/BL: P < 0.001 G2/BL: P < 0.001 Side effects, n (%): G1: 83 (26) G2: 40 (42) Severity of side effects, %: Mild: 72 Severe: 21 Extremely severe: 4 Side effects, %: Dry mouth: 23 Blurred vision: 11 Nausea/vomiting: 6 Dizziness: 6 Headache: 6 Anorexia: 3 Constipation: 3 Drowsiness: 3 Tachycardia: 1 Urinary retention: <1 Allergic Reaction: <1 Discontinued due to AEs, n (%): 66 (16) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: ++ Drop-out rates: ++ Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: + Length of followup: − Measurement methods: + Measurement reliability: − Intervention description: +
Author: Boone et al., 2002 Country and setting: US, Multicenter (86.0% of physicians in private-practice) Enrollment period: NR Funding: Alza Pharmaceuticals Author industry relationship disclosures: NR | Design: Prospective observational Intervention: Non-specific/non-specified pharmacologic therapy Groups: G1: persons who started drug therapy (any) at baseline and continued therapy for ≥ 3 mos G2: persons who started drug therapy (any) at baseline but did not continue for 3 mos G3: persons who did not start drug therapy at baseline but were receiving it at 3 mos G4: persons who did not start drug therapy at baseline and were not receiving therapy at 3 mos G5: persons who were on drugs at 3 mos and 6 mos G6: persons who were on drugs at 3 mos and not at 6 mos G7: persons who were on not drugs at 3 mos and on drug at 6 mos G8: persons on no drugs at 3 mos and 6 mos N at enrollment: Total: 213 N at follow-up: G1: 39 G2: 11 G3: 19 G4: 53 G5: 43 G6: 8 G7: 7 G8: 42 Women, n (%): G1-G2: 40 (80) G3-G4: 64 (88.9) Age, mean ± SD: G1-G2: 62.3 ± 11.9 G3-G4: 60.3 ± 16.4 Race/ethnicity, n (%): White: 94 (77.7) Black: 17 (14.0) Hispanic: 7 (5.8) Asian: 2 (1.7) Other: 1 (0.8) | Inclusion criteria: • Age ≥ 18 • Fluent in English • US resident • Urgency and ≥ 1 incontinence episodes/day • ≥ 8 voids/day • ≥ 3 nocturia episodes/day Exclusion criteria: • Neurogenic condition causing incontinence • Persistent or recurrent UTI • History of interstitial cystitis • Bladder cancer • Previous bladder augmentation surgery • Spinal injury • Alzheimer’s disease • Other dementia • Obstruction of urinary tract • Primary diagnosis of SUI • Enrolled in another study involving medication • Pharmacologic treatment for OAB during previous year | Incontinence episodes/day, mean ± SD: Total: 2.2 ± 3.4 G1-G2: 2.34 G3-G4: 2.09 Duration of symptoms (yrs), mean ± SD: Total: 8.1 ± 10.3 G1-G2: 8.5 ± 12.0 G3-G4: 7.8 ± 9.1 Symptom severity, n (%): Mild: G1-G2: 11 (22.0) G3-G4: 18 (25) Moderate G1-G2: 26 (52.0) G3-G4: 43 (59.7) Severe G1-G2: 13 (26.0) G3-G4: 11 (15.3) Symptom severity worsening, n (%): G1-G2: 28 (56.0) G3-G4: 37 (51.4) U-UDI score, mean ± SD: G1-G2: 1.99 ± 0.79 G3-G4: 1.99 ± 0.88 Non-drug interventions, mean ± SD: G1-G2: 0.40 ± 0.49 G3-G4: 0.47 ± 0.65 Pads/week, mean ± SD: G1-G2: 0.30 ± 1.34 G3-G4: 0.17 ± 0.56 | Improvement in OAB sx, 3 mos, n (%): G1: 30 (76.9) G2: 7 (63.6) G3: 10 (52.6) G4: 19 (35.8) G1-G2/G3-G4: P < 0.001 Moderate to great improvement in OAB sx, n (%): G1-G2: 26 (52.0) G3-G4: 21 (29.2) G1-G2/G3-G4: P = 0.014 Pads/week, 3 mos, mean % change: G1-G2: −25.4 G3-G4: 135.2 Physician visits, mean: G1: 0.15 G2: 0.64 G3: 1.16 G4: 0.26 G1-G2/G3-G4: P = 0.096 Patients pre-scribed nondrug intervention(s), 3 mos, n (%): G1-G2: 5 (10.0) G3-G4: 16 (22.2) G1-G2/G3-G4: P = 0.092 Patients with improvement in OAB sx, 4–6 mos, n (%): G5: 35 (81.4) G6: 1 (12.5) G7: 2 (28.6) G8: 12 (28.6) Pads/week, 4–6 mo, % change: G5: 23 G6: 25 G7: 0 G8: 16 Physician visits, 4–6 mo, mean: G5: 0.16 G6: 0.38 G7: 0.43 G8: 0.05 Predictors of OAB symptom improvement, OR (95 %CI): Rx at baseline: 4.3 (1.8–9.9) Incontinence episodes/day: 3.2 (1.2–8.4) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: − Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: NR Baseline characteristics: − Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: −
Author: Burgio et al., 1998 Country and setting: US, academic health center outpatient geriatric medicine clinic Enrollment period: July 1989 to August 1995 Funding: National Institutes on Aging Author industry relationship disclosures: NR | Design: RCT, placebo controlled Computer-generated random numbers using a block size of 6, w/prior stratification by type and severity of incontinence Intervention: Biofeedback-assisted behavioral vs. drug treatment (oxybutynin chloride; possible range of doses 2.5 mg/d-5.0 mg t.i.d.) vs. placebo All patients had 4 visits over an 8-week period. Patients in G1 had biofeedback added to behavioral training in absence of 50% improvement by session 3. Groups: G1: Behavioral ± biofeedback G2: Pharmacologic G3: Placebo N at enrollment: 468 screened 271 not eligible 197 randomized G1: 65 G2: 67 G3: 65 N at follow-up: G1: 61 G2: 55 G3: 53 Women, %: 100 Age, yrs ± SD: G1: 67.3 ± 7.6 G2: 68.2 ± 7.5 G3: 67.6 ± 7.6 Race/ethnicity,: NR Parity mean ± SD: G1: 2.8 ± 2.0 G2: 2.1 ± 1.4 G3: 2.7 ± 1.8 P < 0.05 | Inclusion criteria: • Community-dwelling women at least age 55 • Ambulatory • At least 2 urge accidents per week by baseline bladder diary • Urge incontinence as predominant pattern • Urodynamic evidence of bladder dysfunction Exclusion criteria: • Continual leakage • Postvoid residual urine volume >200mL • Uterine prolapse past the introitus • Narrow-angle glaucoma • Unstable angina • Decompensated congestive heart failure • Hx of malignant arrhythmias • MMSE <20 (Dementia) | Duration of symptoms, mean yrs ± SD: G1: 9.4 ± 10.8 G2: 9.8 ± 11.9 G3: 12.7 ± 15.9 Restricted activity, (%): G1: 30.8 G2: 32.8 G3: 38.5 UUI only, %: G1: 49.2 G2: 49.3 G3: 47.7 Accidents per week, mean ± SD: G1: 15.8 ± 14.5 G2: 15.9 ± 14.1 G3: 15.4 ± 13.4 P = .98 Severity classification, %: Mild (<5 accidents/wk) G1: 18.5 G2: 17.9 G3: 18.5 Moderate (5–10 accidents/wk) G1: 29.2 G2: 29.9 G3: 27.7 Severe (>10 accidents/wk) G1: 52.3 G2: 52.2 G3: 53.8 Previous treatment with surgery, %: G1: 20.0 G2: 26.9 G3: 29.2 Previous treatment with medication, %: G1: 27.7 G2: 35.8 G3: 30.8 Using estrogen, %: G1: 32.3 G2: 38.8 G3: 35.4 Using diuretics, %: G1: 20.0 G2: 14.9 G3: 12.3 | Accidents per week, mean ± SD: G1: 2.8 ± 4.7 G2: 5.7 ± 9.8 G3: 8.2 ± 11.6 P = .005 Percent reduction, mean ± SD: G1: 80.7 ± 24.8 G2: 68.5 ± 37.2 G3: 39.4 ± 80.0 P < 0.001 Percent reduction, range: G1: −0.9 – 100 G2: −85.7 – 100 G3: −400.0 – 100 Patient perceptions of progress in treatment, %: Much better G1: 74.1 G2: 50.9 G3: 226.9 Better: G1: 25.9 G2: 30.9 G3: 38.5 About the same: G1: 0.0 G2: 16.4 G3: 28.8 Worse: G1: 0.0 G2: 1.8 G3: 5.8 Estimate of % improvement, mean ± SD: G1: 81.6 ± 18.6 G2: 66.4 ± 35.4 G3: 45.1 ± 36.6 Having fewer accidents, %: G1: 100.0 G2: 87.3 G3: 67.3 Accidents are smaller, %: G1: 87.3 G2: 78.8 G3: 54.0 Able to wear less protection, %: G1: 76.0 G2: 56.0 G3: 334.1 Comfortable enough with treatment to continue indefinitely, %: G1: 96.5 G2: 54.7 G3: 43.1 Patient satisfaction with progress, %: Completely satisfied: G1: 77.6 G2: 54.7 G3: 43.1 Somewhat satisfied: G1: 22.4 G2: 40.0 G3: 34.0 Not at all satisfied: G1: 0.0 G2: 10.9 G3: 38.0 Wish to receive another form of treatment, %: G1: 14.0 G2: 75.5 G3: 75.5 P < 0.001 for all comparisons Adverse effects, p compared to placebo G3: Dry mouth, %: G1: 34.9 G2: 96.9 G3: 54.8 P < 0.001 Inability to void, %: G1: 6.3 G2: 21.5 G3: 3.2 P = 0.002 Constipation, %: G1: 22.2 G2: 38.5 G3: 37.1 P = 0.10 Blurred vision, %: G1: 9.5 G2: 15.4 G3: 9.7 P = 0.50 Confusion, %: G1: 6.3 G2: 7.7 G3: 11.3 P = 0.59 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Burgio et al. 2000 [See Burgio et al., 1998] Country and setting: US, University based Enrollment period: two weeks after completion of Burgio et al. 1998 Funding: National Institute on Aging Author industry relationship disclosures: NR | Design: Modified crossover of RCT Intervention: Participants whose treatment was not completely successful were given the opportunity to switch or use combined treatment; further reductions in incontinence were measured. Groups: [underlined: Treatment Changes:] G1: Previous oxybutynin to behavioral modification alone G2: Previous behavior alone to 2.5 mg oxybutynin t.i.d. + behavioral therapy G3: Previous oxybutynin alone to 2.5 mg oxybutynin t.i.d. + behavioral therapy G4: Placebo to behavioral G5: Placebo to oxybutynin N at enrollment G1: 19 G2: 8 G3: 27 G4: 34 G5: 10 N at follow-up: G1: 18 G2: 8 G3: 26 G4: NR G5: NR | Inclusion criteria: •Community-dwelling women at least age 55 •Ambulatory •At least 2 urge accidents per week by baseline bladder diary •Urge incontinence as predominant pattern •Urodynamic evidence of bladder dysfunction •Not completely dry or satisfied with previous, 8-wk treatment Exclusion criteria: •Continual leakage •Postvoid residual urine volume >200mL •Uterine prolapse past the introitus •Narrow-angle glaucoma •Unstable angina •Decompensated congestive heart failure •Hx of malignant arrhythmias •MMSE <20 (Dementia) | Incontinence, after previous study (at baseline), mean % reduction: G1: 59.1 G2: 57.5 G3: 72.7 G4: 22.9 G5: 44.8 | Incontinence, final mean % reduction: G1: 77.1, P = 0.109 G2: 88.5, P = 0.034 G3: 84.3 P = 0.001 G4: 63.9 P = 0.002 G5: 76.5 P = 0.012 Note: 29.2 of G3 declined to continue with drug therapy once they received behavioral modification. Numbers were too low to compare across groups. | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Burgio et al., 2001 [See Burgio et al,. 1998] Country and setting: US, University based Enrollment period: [See Burgio et al,. 1998] Funding: NIH Author industry relationship disclosures: NR | Design: RCT Intervention: Psychological distress associated with pharmacologic treatment vs. behavioral vs. placebo Groups: G1: Behavioral training with biofeedback, 4 visits G2: Oxybutynin 2.5 mg po t.i.d., up to a max of 5 mg t.i.d. G3: Placebo N at enrollment: 197 women N treated: 169 N at follow-up: 155 (completed both pre and post-treatment psychological assessment) Age yrs, mean ± SD: 67.5 ± 7.2 Women, %: 100 Race/ethnicity, %: White: 97 African American: 3 | Inclusion criteria: •≥ 55 yrs old •Ambulatory •UUI ≥2x/wk (2 wk bladder diary), persisting x 3 mo •Predominant UUI (vs. other forms incontinence) •Urodynamic evidence of bladder dysfunction (DI or maximal capacity ≤350 mL) •Exclusion criteria: •Contraindication to oxybutynin or behavioral treatment •Continual leakage •PVR > 200 mL •Uterine prolapse beyond the introitus •Decompensated CHF •Hx of malignant arrhythmias •Impaired mental status (MMSE <20) | SCL-90-R scores ± SD: Somatization G1: 56.0 (10.6) G2: 51.4 (10.8) G3: 52.4 (11.1) Obsessive-Compulsive: G1: 56.5 (10.7) G2: 56.6 (11.4) G3: 57.7 (10.0) Interpersonal Sensitivity G1: 53.8 (11.0) G2: 51.4 (11.9) G3: 50.4 (12.0) Depression G1: 54.7 (10.0) G2: 52.5 (9.7) G3: 51.0 (11.9) Anxiety G1: 48.7 (13.9) G2: 46.8 (12.0) G3: 47.2 (12.8) Hostility G1: 49.3 (10.7) G2: 45.9 (10.1) G3: 48.3 (10.4) Phobia G1: 47.5 (10.2) G2: 46.7 (10.3) G3: 45.7 (8.5) Paranoid Ideation G1: 48.6 (12.4) G2: 49.3 (11.1) G3: 46.1 (12.8) Psychoticism G1: 54.1 (10.7) G2: 52.1 (10.3) G3: 50.5 (11.2) Global Severity G1: 54.2 (11.1) G2: 52.5 (10.3) G3: 52.4 (11.2) 155 participants were compared to the 42 who did not complete intervention and psychological assessment, higher scores (greater distress) on 6 of 10 SCL-90-R scales (somatization, obsessive/compulsive, depression, hostility, paranoid ideation, global severity index), all p values <0.05 Normal range, score 0–63 >75% in normal range (including dropouts) on 9 of 10 scales Highest impairment rate: 33% scored abnormal for obsessive-compulsive | Reduction in incontinence episodes: G1: 83.3% G2: 74.4% G3: 41.4% P<0.001 SCL-90-R scores ± SD: Somatization G1: 51.8 (11.4) G2: 51.2 (9.8) G3: 49.8 (13.0) Obsessive-Compulsive: G1: 53.8 (13.9) G2: 53.9 (10.9) G3: 55.4 (11.0) Interpersonal Sensitivity G1: 49.5 (12.0) G2: 48.9 (11.2) G3: 49.2 (11.3) Depression G1: 51.5 (11.5) G2: 50.6 (10.7) G3: 51.4 (11.2) Anxiety G1: 46.1 (14.6) G2: 44.5 (12.3) G3: 45.8 (12.9) Hostility G1: 44.9 (10.8) G2: 44.6 (10.5) G3: 47.3 (11.2) Phobia G1: 47.1 (11.2) G2: 45.0 (8.3) G3: 45.1 (8.5) Paranoid Ideation G1: 45.8 (10.9) G2: 47.2 (11.6) G3: 47.2 (12.0) Psychoticism G1: 49.2 (11.7) G2: 50.4 (9.7) G3: 49.6 (10.3) Global Severity G1: 50.8 (12.8) G2: 50.4 (10.0) G3: 51.4 (10.9) Correlations between reduction of incontinence and changes in psychological symptoms Somatization G1: 0.28* G2: −0.09 G3: 0.17 Obsessive-Compulsive G1: 0.01 G2: −0.14 G3: 0.02 Interpersonal Sensitivity G1: −0.09 G2: 0.04 G3: 0.13 Depression G1:−0.04 G2: 0.03 G3: 0.07 Anxiety G1: −0.10 G2: −0.01 G3: 0.34* Hostility G1: −0.10 G2: 0.09 G3: 0.11 Phobic anxiety G1:−0.21 G2: −0.17 G3: 0.02 Paranoid Ideation G1: 0.14 G2: −0.04 G3: −0.06 Psychoticism G1: −0.01 G2: −0.01 G3: 0.13 ***P=0.001 Global Severity Index G1: 0.01 G2: 0.06 G3: 0.45*** *p<0.05 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Methods and blinding: + Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Burgio et al., 2008 Country and setting: US, Academic medical centers Enrollment period: July 2004 to January 2006 Funding: NIH Pfizer Author industry relationship disclosures: 20 of 29 Allergan (3) Alza (1) Astellas Pharma (7) Bionovo (1) Bristol-Meyers Squibb (1) Dynogen (1) Elan (1) Ethicon (2) GSK (4) Johnson & Johnson (3) Lilly (7) Medtronic (1) Merck (1) Novartis (6) Ortho-McNeil (3) Pfizer (>10) Procter & Gamble (3) Q-Med (1) Renessa (1) Sanofi (1) Solace (1) Watson (1) | Design: RCT Intervention: Pharmacologic vs. pharmacologic plus behavioral interventions for 10 wks (Stage 1), followed by no drug therapy (Stage 2) with assessments at 10 wks and 8 mos* Groups: G1: Tolterodine tartrate (ER capsules), 4 mg/d plus behavioral training: pelvic floor muscle control and exercises, behavioral strategies to diminish urgency, suppress bladder contractions and prevent both stress and urge incontinence; delayed voiding; fluid management; handout with hints G2: Tolterodine tartrate (ER capsules), 4 mg/d N at enrollment: 4043 screened 2612 not eligible 870 declined 561 consented 254 excluded 307 randomized G1: 153 G2: 154 N at follow-up: G1: 153 Completed treatment: 107 Outcome known at 8 mos: 119 G2: 154 Completed treatment: 101 Outcome known at 8 mos: 118 Age, mean ± SD: G1: 55.8 ± 14.2 G2: 58.0 ± 13.5 Women, %: 100 Race/ethnicity, n (%): Hispanic: G1: 13 (9) G2: 17 (11) NH White: G1: 105 (69) G2: 85 (56) NH Black: G1: 22 (14) G2: 35 (23) Other: G1: 13 (9) G2: 15 (10) BMI, kg/m^2^ ± SD: G1: 33.2 ± 9.5 G2: 32.3 ± 7.6 | Inclusion criteria: • Women • Community-dwelling • UUI only, or urge-predominant • ≥ 7 episodes of incontinence in a 7-day bladder diary • Persistent incontinence for at least 3 mos • No current use of antimuscarinics or other medications that could affect UI • No evidence of neurogenic etiology Exclusion criteria: • Age < 21 • Pregnant, planning a pregnancy in next 8 mos, or not using birth control • < 6 mos postpartum or termination after 20 wks gestation • Unable to contract pelvic floor muscles during evaluation • Behavioral therapy of > 2 mos in past 2 yrs • Continual leakage or always damp • Hypersensitive to study drug • Systemic disease that affects bladder function • Currently using catheter to empty bladder • Postvoid residual volume > 150mL • Treatment for prolapse with pessary < 3 mos • Incontinence, vaginal, bladder or prolapse surgery in the past 6 mos • Urethral diverticulum • Previous augmentation cystoplasty or artificial sphincter • Neuromodulation for pelvic indications • Using anticholinergic agents, cholinergic agonists, tricyclic antidepressants, or duloxetine in ≤ 4 wks • Using diuretics with dosage change past 3 mos • Uncontrolled medical problem • History of bladder or pelvic cancer or pelvic radiation therapy • Glaucoma • Gastric retention • Non-ambulatory • Participation in other intervention trial that might influence outcome | UUI, 7–13 episodes/week, n (%): G1: 2 (1.3) G2: 2 (1.3) UUI, ≥ 14 episodes/week, n (%): G1: 2 (1.3) G2: 4 (2.6) MUI, 7–13 episodes/week, n (%): G1: 46 (29.9) G2: 46 (30.1) MUI, ≥ 14 episodes/week, n (%): G1: 104 (67.5) G2: 101 (66.0) Adjusted incontinence episodes/week, mean: G1: 23.1 G2: 23.2 Previous non-surgical treatment for incontinence, n (%): G1: 19 (12) G2: 22 (14) | Success, n (%): G1: 43 (28) G2: 41 (27) Failure, n (%): G1: 75 (49) G2: 78 (51) Success rate, 8 months, lifetable analysis, % (95% CI): G1: 41 (32, 50) G2: 41 (33, 50) G1/G2: 0 (−12, 12) Success rate, 8 months, complete cases, % (95% CI): G1: 36 (27, 45) G2: 34 (25, 43) G1/G2: 2 (−10, 14) Success rate, 8 mos, assuming missings were failures, % (95% CI): G1: 28 (21, 35) G2: 27 (20, 34) G1/G2: 1 (−9, 11) Adjusted incontinence episodes/week, after Stage 1, mean: G1: 2.7 G2: 4.7 Adjusted incontinence episodes/week, after Stage 1, mean change: G1: −20.4 G2: −18.5 G1/G2: −1.9 (−5.9, 2.0) Achieved 70% reduction in incontinence episodes, per bladder diary, 10 weeks (%): G1: 69 G2: 58 G1/G2: 11 (−0.3, 22.1) Totally dry, per bladder diary, 10 weeks (%): G1: 21 G2: 17 Voids/day, mean change: G1: 0.5 G2: −0.4 G1/G2: 0.9 (0.3, 1.5) Symptom Distress Scores: G1/G2: P < 0.0001 Symptom Bother Scores (OAB-q), Stage 1, mean change: G1: −36.7 G2: −30.4 G1/G2: P < 0.0001 Symptom Bother Scores (OAB-q), Stage 2, mean change: G1: −30.9 G2: −20.4 G1/G2: P < 0.0001 Patient completely satisfied, Stage 1, %: G1: 53 G2: 40 G1/G2: 13 (1, 25) Patient completely satisfied, 8 months, %: G1: 33 G2: 20 G1/G2: 13 (2, 24) Patient better or much better, Stage 1, %: G1: 90 G2: 77 G1/G2: 13 (4, 22) Patient better or much better, 8 months, %: G1: 69 G2: 43 G1/G2: 26 (14, 38) Persistence in perceived improvement, 8 mos, women with improvement at Stage 1: G1: 72 G2: 54 G1/G2: 17 (4, 30) Harms: G1: 3 participants 1: blurred vision, syncope, night sweats, stomach cramping and weakness 2: 2 episodes of small-bowel obstruction and an allergic reaction (pruritus and rash) 3: tachycardia during stage 2 G2: 3 participants 1: small bowel obstruction 2: peripheral edema 3: renal cell carcinoma diagnosis during stage 2 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: − Pt selection criteria: + Loss to followup: − Drop-out rates: ++ Power calculation: + Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Capo et al. 2008 Country and setting: US, 207 centers Enrollment period: NR Funding: Astellas Pharma US, Inc., and GlaxoSmithKline Author industry relationship disclosures: 5 of 5 Astellas (4) Boehringer Mannheim Pharmaceuticals (1) Cephalon Inc. (1) GlaxoSmithKline (3) Reliant Pharmaceuticals (1) Schering Plough Corporation (1) Abbott (1) Akros (1) AstraZenica (1) Johnson & Johnson (1) Lilly (1) Manking (1) Merck (1) Novartis (1) NovoNordisk (1) Pfizer Inc. (1) Solvay (1) Takeda & TAP (1) Pri Med (1) Lucente (1) | Design: RCT Intervention: 12-wk treatment with 5 mg solifenacin succinate. Dosage could be increased at wk 4 and wk 8 to 10 mg, maintained or decreased in response to pt perceived efficacy and tolerability Groups: G1: Hispanic subgroup of G2 G2: full study population including G1 N at enrollment: G1: 94 G2: 2205 N at follow-up, range: G1: 47–80 G2: 1254–2005 Age, yrs ± SD: G1: 51.8 ± 12.8 G2: 59.7 ± 14.4 Weight in lbs, mean ± SD: G1: 171.1±36.4 G2: 182.2±47.0 Race/ethnicity, n (%): Hispanic: G1: 94 (100) G2: 94 (4.3) White: G2: 1761 (79.9) Black: G2: 274 (12.4) Asian: G2: 59 (2.7) Other: G2: 17 (0.8) Women, N (%): G1: 74 (78.7) G2: 1813 (82.2) Parity: NR | Inclusion criteria: • ≥ 18 yrs of age • OAB symptoms ≥3 mos • Toilet without difficulty • Washout of other OAB meds ≥ 7 days • Non-drug treatment of OAB if established ≥ 4 wks prior to study and continued Exclusion criteria: • SUI • Stress predominant MUI • UTI or chronic inflammation clinically significant outflow • Obstruction due to BPH • Narrow-angle glaucoma • Urinary or gastric retention • Severe renal or hepatic impairment • Chronic severe constipation or gastrointestinal obstructive disease • Bladder cancer • Women not using a reliable contraceptive • Hypersensitivity to the study medication, any of its components, or to anticholinergic medication | Urge incontinence, n (%): G1: 63 (67.0) G2: 1586 (71.9) Urinary urgency, n %: G1: 88 (93.6) G2: 2007 (91.0) Frequency, n, (%): G1: 86 (91.5) G2: 1969 (89.3) Nocturia, n (%): G1: 79 (84.0) G2: 1792 (81.3) Patient perception of bladder condition, mean score: G1: 4.0 G2: 4.0 Most bothersome OAB symptom-frequency, n %: G1: 38 (40.4) G2: 619 (28.1) Most bothersome OAB symptom-urinary urgency, n %: G1: 22 (23.4) G2: 508 (23.0) Most bothersome OAB symptom-urge incontinence, n %: G1: 17 (18.1) G2: 602 (27.3) Most bothersome OAB symptom-nocturia, n %: G1: 12 (12.8 G2: 337 (15.3) Most bothersome OAB symptom-none specified, n %: G1: 5 (5.3) G2: 139 (6.3) | Increased dosage 5 mg/day, n (%)-Wk 4: G1: 46 (48.9) Increased dosage 10 mg/day, n (%)-Wk 4: G1: 37 (39.4) Discontinued, n Wk 4: G1: 1 Increased dosage 5 mg/day, n (%)-Wk 8: G1: 31 (33.0) Increased dosage 10 mg/day, n (%)-Wk 8: G1: 39 (41.5) Discontinued-Wk 8, n: 1 Returned to 5 mg/day-Wk 8, n: 5 Increased dosage to 10 mg/day-Wk 8, n: 12 Patient Perception of Bladder, mean Wk 4: G1: 3.3* G2: 3.3* Patient Perception of Bladder, mean Wk 8: G1: 2.8* G2: 2.8* Patient Perception of Bladder, mean Wk 12: G1: 3.0* G2: 2.9* *P <0.001 vs.baseline Symptom bother from VAS, Change from Baseline, mean scores (mm), (95% CI) p-value: Urinary urgency: G1: −39.2 (−45.9, −32.5) P < 0.001 G2: −39.5 (−41.0, −38.1) P < 0.001 Urge Incontinence: G1: −37.7 (−46.0, −29.4) P < 0.001 G2: −40.1 (−41.8, −38.4) P < 0.001 Frequency: G1: −40.0 (−46.9, −33.2) P < 0.001 G2: −41.8 (−43.3, −40.3) P < 0.0001 Nocturia: G1: −43.2 (−50.4, −36.1) P < 0.001 G2: −36.9 (−38.4, −35.4) p < 0.001 OAB-q subscales, change from baseline, mean (95% CI) p-value: Symptom bother: G1: −29.1 (−34.8, −23.4) P < 0.001, G2: −29.6 (−30.7, −28.6) P < 0.001 Coping: G1: 24.0 (18.0, 30.1) P < 0.001 G2: 27.4 (26.2, 28.5) P < 0.001 Concern: G1: 25.8 (19.5, 32.2) P < 0.001 G2: 29.6 (28.4, 30.8) P < 0.001 Sleep: G1: 25.7 (19.4, 32.0) P < 0.001 G2: 27.3 (26.1, 28.5) P < 0.001 Social Interaction G1: 15.9 (11.5, 20.3) P < 0.001 G2: 14.7 (13.7, 15.6) P < 0.001 Overall Health- related QoL: G1: 23.2 (18.0, 28.5) P < 0.001 G2: 25.4 (24.4, 26.4) P < 0.001 Any Adverse Event, n (%): G1: 48 (51.4) G2: 1321 (59.4) Dry mouth, n (%): G1: 17 (18.1) G2: 477 (21.4) Constipation, n (%): G1: 12 (12.8) G2: 295 (13.3) Headache, n (%): G1: 3 (3.2) G2: 76 (3.4) Dizziness, n (%): G1: 2 (2.1) G2: 27 (1.2) Blurred vision, n (%): G1: 4 (4.3) G2: 57 (2.6) Palpitations, n (%): G1: 2 (2.1) G2: 6 (0.3) Upper respiratory tract infection, n (%): G1: 3 (3.2) G2: 68 (3.1) UTI, n (%): G1: 3 (3.2) G2: 76 (3.4) Bronchitis, n (%): G1: 3 (3.2) G2: 31 (1.4) Nasopharyngitis, n (%): G1: 2 (2.1) G2: 50 (2.3) Influenza, n (%): G1: 2 (2.1) G2: 11 (0.5) Insomnia, n (%): G1: 2 (2.1) G2: 17 (0.8) Depression, n (%): G1: 2 (2.1) G2: 19 (0.9) Hypertension, n (%): G1: 2 (2.1) G2: 16 (0.7) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: − Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: NR Baseline characteristics: − Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Cardozo et al., 1993 Country and setting: UK, Denmark, Germany, Netherlands, 4 centers Enrollment period: NR Funding: NR Author industry relationship disclosures: NR | Design: RCT Intervention: Oral oestriol vs. placebo Groups: G1: 3 mg oral estradiol 3mg qd x 12 wks G2: placebo x 12 wks N at enrollment: G1: 34 G2: 30 N at follow-up: G1: 31 G2: 25 Women, %: 100 Age, mean ± SD: G1: 58.9 ± 10.4 G2: 60.2 ± 9.8 Race/ethnicity: NR Height (cm), mean ± SD: G1: 161.9 ± 7.1 G2: 162.9 ± 6.6 Weight (kg), mean ± SD: G1: 70.9 ± 11.6 G2: 69.1 ± 12.6 | Inclusion criteria: • Women • Ambulant • Postmenopausal • Sensory and/or motor urge incontinence (confirmed by urodynamics) Exclusion criteria: • Symptoms present for > 3 years before menopause • Voiding difficulty • Pelvic anatomical defect requiring surgery • Neurological disease • Recent estrogen usage (< 6 mos) • Medication use that could affect bladder or urethral function • Contraindication to estrogen | Daytime incontinence episodes/day, mean ± SD: G1: 3.4 ± 4.2 G2: 3.2 ± 4.7 Nocturnal incontinence episodes/day, mean ± SD: G1: 1.6 ± 6.0 G2: 1.0 ± 2.3 Daytime voids/day, mean ± SD: G1: 10.2 ± 5.0 G2: 10.6 ± 5.4 Nocturia s/day, mean ± SD: G1: 2.0 ± 1.4 G2: 2.6 ± 2.2 Diurnal frequency, %: G1: 26 G2: 20 Nocturia, %: G1: 25 G2: 20 Urgency, %: G1: 29 G2: 25 Dysuria, %: G1: 9 G2: 4 SUI, %: G1: 11 G2: 10 UUI, %: G1: 25 G2: 23 Urgency severity, mean score ± SD: G1: 2.6 ± 0.5 G2: 2.5 ± 0.8 Nocturia severity mean score ± SD: G1: 1.6 ± 0.8 G2: 1.7 ± 1.1 Bladder volume (mL), first desire to void, mean ± SD: G1: 161 ± 74 G2: 163 ± 86 Detrusor pressure (cm H_2_O), mean ± SD: G1: 17 ± 12 G2: 17 ± 17 Max cystometric capacity (mL), mean ± SD: G1: 328 ± 125 G2: 322 ± 113 Max pressure (cm H_2_O), mean ± SD: G1: 31 ± 27 G2: 21 ± 79 | Daytime incontinence episodes/day, 1 mo, mean ± SD: G1: 3.0 ± 3.5 G2: 2.1 ± 2.6 Daytime incontinence episodes/day, 3 mos, mean ± SD: G1: 2.7 ± 3.5 G2: 1.3 ± 2.3 Nocturnal incontinence episodes/day, 1 mo, mean ± SD: G1: 0.6 ± 1.2 G2: 0.7 ± 2.0 Nocturnal incontinence episodes/day, 3 mos, mean ± SD: G1: 0.3 ± 0.7 G2: 0.3 ± 0.8 Daytime voids/day, 1 mo, mean ± SD: G1: 8.9 ± 3.0 G2: 10.6 ± 5.4 Daytime voids/day, 3 mos, mean ± SD: G1: 8.6 ± 3.4 G2: 7.2 ± 2.2 G1/BL: P < 0.05 G2/BL: P < 0.01 Nocturia episodes/day, 1 mo, mean ± SD: G1: 2.0 ± 1.6 G2: 1.5 ± 1.2 Nocturia episodes/day, 3 mos, mean ± SD: G1: 1.5 ± 1.1 G2: 1.4 ± 1.3 G2/BL: P < 0.05 Diurnal frequency, cure %: G1: 6 G2: 9 Nocturia, cure %: G1: 10 G2: 8 P < 0.01 Urgency, cure %: G1: 7 G2: 9 P < 0.01 Dysuria, cure %: G1: 5 G2: 4 SUI, cure %: G1: 6 G2: 6 UUI, cure %: G1: 11 G2: 7 P < 0.01 Urgency severity, 1 mo, mean score ± SD: G1: 1.8 ± 0.8 G2: 1.6 ± 1.0 Urgency severity, 3 mos, mean score ± SD: G1: 1.5 ± 1.1 G2: 1.4 ± 1.1 G1/BL: P < 0.01 G2/BL: P < 0.01 Nocturia severity, 1 mo, mean score ± SD: G1: 1.3 ± 0.8 G2: 1.3 ± 1.0 Nocturia severity, 3 mos, mean score ± SD: G1: 1.0 ± 0.8 G2: 1.0 ± 1.1 G1/BL: P < 0.01 Bladder volume (mL), first desire to void, 3 mos, mean ± SD: G1: 206 ± 142 G2: 202 ± 142 G1/BL: P < 0.05 Detrusor pressure (cm H_2_O), 3 months, mean ± SD: G1: 17 ± 15 G2: 22 ± 39 Max cystometric capacity (mL), mean ± SD: G1: 333 ± 163 G2: 365 ± 136 Max pressure (cm H_2_O), mean ± SD: G1: 25 ± 20 G2: 32 ± 65 G1/BL: P < 0.05 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: ++ Power calculation: + Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Cardozo et al., 2004 [See evidence table for Kelleher et al., 2005] Country and setting: 84 centers in Denmark, UK, Czech Republic, Australia, Netherlands, Russia, US Enrollment period: NR Funding: NR Author industry relationship disclosures: NR | Design: RCT Intervention: Solifenacin 5 mg vs. solifenacin 10 mg vs. placebo, 12 weeks once daily therapy Groups: G1: Solifenacin 5 mg qd G2: Solifenacin 10 mg qd G3: Placebo N at enrollment: 911 N treated: G1: 299 G2: 307 G3: 301 N at follow-up, first visit: G1: 286 G2: 290 G3: 281 N at follow-up, study completion: G1: 277 G2: 283 G3: 270 Women, n (%): G1: 237 (82.9) G2: 238 (82.1) G3: 227 (80.8) Age, mean ± SD (range): G1: 55.4 ± 13.8 (19–85) G2: 55.9 ± 14.2 (18–83) G3: 56.1 ± 13.3 (18–82) Race/ethnicity, n (%): White: G1: 280 (97.9) G2: 281 (96.9) G3: 274 (97.5) Black: G1: 2 (0.7) G2: 2 (0.7) G3: 3 (1.1) Asian: G1: 4 (1.4) G2: 6 (2.1) G3: 2 (0.7) Other: G1: 0 G2: 1(0.3) G3: 2 (0.7) Weight (kg), mean ± SD: G1: 74.1 ± 15.0 G2: 74.6 ± 15.4 G3: 74.1 ± 14.4 | Inclusion criteria: • Age ≥ 18 • Symptoms of OAB (including urinary frequency with urgency and/or UUI) for ≥3 months • ≥ 8 voids/day • ≥ 3 episodes urinary incontinence during 3-day diary period Exclusion criteria: • BOO • PVR volume >200 mL • Stress predominant MUI • Neurological cause for detrusor overactivity • UTI or bladder stones • Previous pelvic irradiation • Malignant disease of pelvic organs • Contraindication to antimuscarinic medication • Narrow-angle glaucoma • Urinary or gastric retention • Non drug treatment for OAB 2 wks before study • Diabetic neuropathy • Drugs to treat incontinence • Drugs with cholinergic or anticholinergic side-effects • Participation in a clinical trial within 30 days • Childbearing potential, pregnant or nursing or not using reliable contraceptive methods | UUI, n (%): 405 (47) Urinary incontinence, n (%): 491 (57) Voids/day, range: 12.05–12.31 Duration of symptoms (months), median (range): G1: 27.0, 4–383) G2: 28.0, 4–314) G3: 29.0, 5–327) Prior drug therapy, n (%): G1: 101 (35.3) G2: 94 (32.5) G3: 95 (33.8) Any other non-drug therapy, n (%): G1: 64 (22.4) G2: 77 (26.6) G3: 94 (33.5) | UUI episodes/day, mean change (% change): G1: −1.3 (−62.7) G2: −1.21 (−57.1) G3: −0.91 (−42.5) G1/BL: P = 0.014* G2/BL: P = 0.042* Urgency episodes/day, mean change (95% CI for difference): G1: −2.84 (−1.44, −0.28) G2: −2.90 (−1.49, −0.35) G3: −1.98 G1/G3: P = 0.003 G2/G3: P = 0.002 Incontinence episodes/day, mean change (% change): G1: −1.63 (−60.7) G2: −1.57 (−51.9) G3: −1.25 (−27.9) G1/BL: P = 0.002* G2/BL: P = 0.016* Incontinent patients with no incontinence at end of study, %: G1: 50.3 G2: 49.7 Voids/day, mean change (95% CI for difference): G1: −2.37 (−1.27, −0.29) G2: −2.81 (−1.71, −0.72) G3: −1.59 G1/G3: P = 0.0018 G2/G3: P = 0.0001 Nocturia episodes/day, mean change (95% CI for difference): G1: −0.58 G2: −0.71 (−0.38, −0.01) P = 0.005 G3: −0.52 G1/G3: P = 0.48 G2/G3: P = 0.036 KHQ, general health perception, mean change: G1: −5.8 G2: −4.5 G3: −2.3 KHQ, incontinence impact, mean change: G1: −27.0 G2: −30.3 G3: −20.1 G1/BL: P < 0.01 G2/BL: P < 0.001 KHQ, role limitations, mean change: G1: −21.9 G2: −24.4 G3: −15.9 G1/BL: P < 0.01 G2/BL: P < 0.001 KHQ, physical limitations, mean change: G1: −19.2 G2: −22.3 G3: −15.4 G2/BL: P < 0.001 KHQ, social limitations, mean change: G1: −12.1 G2: −11.7 G3: −9.0 KHQ, personal relationships, mean change: G1: −8.5 G2: −8.3 G3: −9.4 KHQ, emotions, mean change: G1: −16.4 G2: −16.6 G3: −12.2 G1/BL: P < 0.05 G2/BL: P < 0.05 KHQ, sleep/energy, mean change: G1: −15.4 G2: −15.9 G3: −11.4 G1/BL: P < 0.05 G2/BL: P < 0.05 KHQ, severity measures, mean change: G1: −9.6 G2: −11.8 G3: −7.2 G2/BL: P < 0.01 KHQ, symptom severity, mean change: G1: −3.4 G2: −3.4 G3: −2.4 G1/BL: P < 0.01 G2/BL: P < 0.01 Voided volume (mL), mean change (95% CI for difference): G1: 30.8 (12.4–27.2) G2: 36.0 (17.7–33.0) G3: 10.67 G1/G3: P = 0.0001 G2/G3: P = 0.0001 Dry mouth, n (%): G1: 23 (7.7) G2: 71 (23.1) G3: 7 (2.3) Dry mouth, mild, n (%): G1: 18 (6.0) G2: 55 (17.9) G3: 5 (1.7) Dry mouth, moderate, n (%): G1: 5 (1.7) G2: 15 (5.2) G3: 1 (0.3) Dry mouth, severe, n (%): G1: 0 G2: 0 G3: 1 (0.3) Constipation, n (%): G1: 11 (3.7) G2: 28 (9.1) G3: 6 (2.0) Constipation, mild, n (%): G1: 9 (3.0) G2: 16 (5.2) G3: 5 (1.7) Constipation, moderate, n (%): G1: 5 (1.7) G2: 15 (5.2) G3: 1 (0.3) Constipation, severe, n (%): G1: 0 G2: 2 (0.7) G3: 0 Blurred vision, n (%): G1: 12 (4.0) G2: 18 (5.9) G3: 7 (2.3) Blurred vision, mild, n (%): G1: 7(2.3) G2: 14 (4.6) G3: 6 (2.0) Blurred vision, moderate, n (%): G1: 4 (1.3) G2: 4 (1.3) G3: 1 (0.3) Blurred vision, severe, n (%): G1: 1 (0.3) G2: 0 G3: 0 Discontinued due to AEs, n (%): G1: 7 (2.3) G2: 12 (3.9) G3: 10 (3.3) | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: − Masking: + Pt selection criteria: + Loss to followup: ++ Drop-out rates: ++ Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Cardozo et al., 2008 Country and setting: Europe, Community Enrollment period: April 2004 to October 2005 Funding: Astellas Pharma Europe Ltd Author industry relationship disclosures: 9 of 9 Apogepha (1) Astellas (9) BARD (1) Bayer-Schering (1) Boston Scientific (1) Cook (1) Gynecare (1) J&J (1) Lilly (3) Merckle Recordati (1) Organon (1) Pfizer (3) Plethora (1) Recordati (1) Sanofi-Aventis (1) UCB (1) | Design: Multicenter randomized double blind placebo-controlled 2 week run in Intervention: Solifenacin 5 or 10 mg daily (pts requesting dose increase to 10 mg at 8 weeks were randomized in a 1:1 ratio to 5 mg or 10 mg) Groups: G1: Solifenacin 5 or 10 mg daily G2: Placebo N at enrollment: G1: 640 G2: 223 N at follow-up: G1: 505 G2: 223 Women, %: G1: 89.1 G2: 85.7 Age, mean: G1: 57.7 G2: 57.9 Race/ethnicity, %: White: G1: 98.4 G2: 99.1 Black: G1: 0.4 G2: 0.4 Asian: G1: 0.8 G2: 0 Other: G1: 0.4 G2: 0.4 Follow-up: 16 weeks | Inclusion criteria: • Age ≥ 18 • Male or female • OAB symptoms of urgency, frequency, urge incontinence ≥ 3 months • ≥ 3 episodes of urgency with or without incontinence in last 3 days • Mean of ≥ 8 voids/day Exclusion criteria: • Clinically significant BOO • PVR > 200 mL • UTI • Bladder stones • IC • Previous irradiation • Malignant pelvic disease • Sexually active women practicing an unreliable method of birth control • Pregnancy/lactation • Conditions contraindicating anticholinergic medication | UUI episodes/day, mean: G1: 1.63 G2: 2.01 Severe urgency episodes (PPIUS 3+4)/day, mean: G1: 5.11 G2: 5.54 Urgency episodes (PPIUS 1–4)/day, mean: G1: 10.72 G2: 10.81 Maximum urgency intensity (PPIUS)/day, mean: G1: 3.53 G2: 3.59 Incontinence episodes/day, mean: G1: 1.58 G2: 1.96 Voids/day, mean: G1: 11.10 G2: 11.14 PPBC score, mean: G1: 5 G2: 5 Urgency bother score, VAS (mm), mean: G1: 68 G2: 69 Treatment satisfaction score, VAS (mm), mean: G1: 29 G2: 29 | UUI episodes/day, mean change ± SD: G1: −1.7 ± 2.2 (N=326) G2: −1.3 ± 2.0 (N=158) P = 0.0002 Severe urgency episodes (PPIUS 3+4)/day, mean ± SD: G1: −2.6 ± NR (N=503) G2: −1.8 ± NR (N= 216) P < 0.0001 Urgency episodes (PPIUS 1–4)/day, mean ± SD: G1: −2.3 ± 3.0 (N=503) G2: −1.6 ± 3.3 (N=216) P = 0.0006 Maximum urgency intensity (PPIUS)/day, mean change ± SD: G1: −0.8 ± 0.9 (N=503) G2: −0.6 ± 0.9 (N=216) P = 0.0006 Incontinence episodes/day, mean change ± SD: G1: −1.7 ± 2.2 (N=329) G2: −1.4 ± 2.0 (N=158) P = 0.0003 Voids/day, mean change ± SD: G1: −2.1 ± 2.6 (N= 502) G2: −1.3 ± 2.7 (N= 216) P < 0.0001 PPBC score, median % change: G1: −33 G2: −20 P < 0.0001 Urgency bother score, VAS (mm), median % change: G1: −59 G2: −35 P < 0.0001 Treatment satisfaction score, VAS (mm), median % change: G1: 66 G2: 34 P < 0.0001 Withdrawn due to AEs, n: G1: 17 G2: 6 Dry mouth, %: G1: 15.8 G2: 2.7 P < 0.001 Constipation, %: G1: 6.9 G2: 2.2 P = NS Blurred Vision, %: G1: 0.8 G2: 0.9 P = NS | Quality: Overall quality score: good INTERNAL VALIDITY: good Randomization: + Method and blinding: + Pt selection criteria: + Loss to followup: ++ Drop-out rates: ++ Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Chancellor et al., 2000 Country and setting: 167 centers in Europe, North America, Australia Enrollment period: NR Funding: Pharmacia & Upjohn Author industry relationship disclosures: NR | Design: randomized, double-blind, placebo-controlled, parallel-group Intervention: tolterodine vs. placebo Groups: G1: tolterodine 2 mg b.i.d. × 12 wks G2: placebo × 12 wks N at enrollment: G1: 514 G2: 508 N at follow-up: G1: 514 G2: 508 Age, mean yrs (range): G1: 60 (22–92) G2: 61 (21–93) Women, N (%): 818 (80%) Race/ethnicity: NR | Inclusion criteria: • ≥18 years • ≥5 incontinence episodes/wk • Average ≥8 voids/24 hr • OAB symptoms • ≥6 mos Exclusion criteria: • Stress incontinence • Total daily urine volume >3L • Contra-indications to antimuscarinic therapy • Hepatic/renal disorders • Symptomatic or history of recurrent UTI • BOO • Haematuria • Interstitial cystitis • Receiving bladder training, electro-stimulation therapy • Indwelling or intermittent catheter • Pregnant or nursing • Women not using reliable contraception • Concomitant treatment for OAB (other than ERT for at least 2 mos) • Use of agents or drugs with potential to inhibit cytochrome P4503A4 isoform | Previous drug therapy for OAB, %: G1: 54 G2: 52 Good efficacy response, %: G1: 62 G2: 59 Incontinence episodes/week, mean (range): G1: 23.2 (0–168) G2: 23.3 (0–168) ≥5 incontinence episodes/week, n (%): G1: 494 (97) G2: 498 (97) Voids/day, mean (range): G1: 11.1 (2–48.6) G2: 11.3 (2–37.4) ≥8 voids/day, n (%): G1: 469 (91) G2: 467 (92) Voided volume (mL), mean (range): G1: 137 (38–283) G2: 136 (21–374) Pads/day, mean (range): G1: 1.4 (0–25) G2: 1.5 (0–22) | Incontinence episodes/week, mean change ± SD: G1: −10.6 ± 16.9 G2: −6.9 ± 15.4 P = 0.0005* Voids/day, mean change ± SD: G1: −1.7 ± 3.3 G2: −1.2 ± 2.9 P = 0.0079* Voided volume (mL), mean change ± SD: G1: +29 ± 47 G2: +14 ± 41 P = 0.0001* Pads/day, mean change ± SD: G1: −0.5 ± 1.8 G2: −0.2 ± 1.4 P = 0.0035* Improvement, n (%): G1: 313 (61) G2: 218 (43) No change, n (%): G1: 158 (31) G2: 225 (44) Deterioration, n (%): G1: 43 (8) G2: 65 (13) Mild dry mouth, n (%): G1: 93 (18) G2: 31 (6) Moderate dry mouth, n (%): G1: 50 (10) G2: 8 (2) Severe dry mouth, n (%): G1: 12 (2) G2: 0 Constipation, n (%): G1: 35 (7) G2: 22 (4) Headache, n (%): G1: 19 (4) G2: 23 (5) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Chancellor, Kianifard, et al., 2008 Country and setting: US Enrollment period: May 2005 to February 2006 Funding: NR Author industry relationship disclosures: 6 of 7 Genaera (1) Novartis (6) | Design: Randomized open-label Intervention: Behavioral modification in addition to darifenacin (allowed to increase dose from darifenacin 7.5 mg to 15 mg daily after 2 weeks) Groups:* G1: Darifenacin G2: Darifenacin and behavioral modification N at enrollment: G1: 190 G2: 205 N at follow-up, 12 weeks: G1: 173 G2: 175 Age, mean ± SD: G1: 57.4 ± 13.1 G2: 58.4 ± 14.6 Race/ethnicity: White: G1: 90 G2: 88.3 Other (non-white): G1: 10 G2: 11.7 Women, %: G1: 90 G2: 88.3 | Inclusion criteria: • ≥ 8 voids/day • ≥ 2 UUI episodes/day • ≥ 2 episodes of urgency/day Exclusion criteria: • Any drug with bladder effects for 2 weeks prior to study participation • Participation in any formal bladder-training program within 30 days of screening • Predominant SUI • Bladder or neurologic condition that could affect bladder function or in which use of anticholinergics was contra-indicated | UUI episodes/day, mean ± SD: G1: 2.78 ± 2.57 G2: 3.00 ± 2.56 UUI episodes/day, median: G1: 2.33 G2: 2.58 Mean UUI episodes/day, total population, n (%): 0 episodes: G1: 36 (19.1) G2: 29 (14.2) 1–6 episodes: G1: 138 (73.0) G2: 155 (76.0) 7–13 episodes: G1: 15 (7.9) G2: 20 (9.8) ≥14 episodes G1: 0 (0.0) G2: 0 (0.0) Mean UUI episodes/day, age ≥ 65, n (%) 0 episodes G1: 9 (17.0) G2: 8 (9.9) 1–6 episodes G1: 40 (75.5) G2: 63 (77.8) 7–13 episodes G1: 4 (7.5) G2: 10 (12.3) Urgency episodes/day, mean ± SD: G1: 10.88 ± 3.80 G2: 10.58 ± 4.00 Urgency episodes/day, median: G1: 10.67 G2: 10.33 Voids/day, mean ± SD: G1: 11.92 ± 3.03 G2: 11.75 ± 3.37 Voids/day, median: G1: 11.33 G2: 11.33 Nocturia episodes/day, mean ± SD: G1: 1.77 ± 1.43 G2: 1.87 ± 1.35 Nocturia episodes/day, median: G1: 1.67 G2: 1.67 Pads used/day, mean ± SD: G1: 1.12 ±1.93 G2: 0.99 ± 1.67 Pads used/day, median: G1: 0 G2: 0 | UUI episodes/day mean change ± SD: G1: −1.89 ± 2.29 G2: −2.10 ± 2.32 G1/G2: P = 0.268 UUI episodes/day median change (95% CI): G1: −1.33 (−2.00, −1.00) G2: −2.00 (−2.00, −1.33) Urgency episodes/day mean change ± SD: G1: −2.87 ± 3.59 G2: −2.68 ± 3.54 G1/G2: P = 0.882 Urgency episodes/day median change (95% CI): G1: −2.33 (−3.00, −1.67) G2: −2.67 (−3.00, −2.00) Voids/day, mean change ± SD: G1: −2.96 ± 2.91 G2: −2.82 ± 2.87 G1/G2: P = 0.681 Voids/day, median change (95% CI): G1: −2.67 (−3.33, −2.00) G2: −2.67 (−3.00, −2.33) Nocturia episodes/day, mean change ± SD: G1: −0.65 ± 1.26 G2: −0.67 ± 1.21 G1/G2: P = 0.315 Nocturia episodes/day, median change (95% CI): G1: −0.67 (−0.67, −0.33) G2: −0.67 (−0.67, −0.33) Pads used/day mean change ± SD: G1: −0.72 ±1.54 G2: −0.61 ± 1.28 G1/G2: P = 0.978 Pads used/day median change (95% CI): G1: 0 (0,0) G2: 0 (0,0) Side effects, %: Constipation: 18.5 Dry mouth 25 UTI: 4.8 Headache: 3.8 Discontinued due to adverse event(s), n (%) G1: 6 (3.2) G2: 21 (10.25) Discontinued due to constipation, %: 2 Discontinued due to dry mouth, %: 1.8 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: − Pt selection criteria: + Loss to followup: + Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Chancellor, Zinner et al., 2008 Country and setting: USA, multicenter Enrollment period: NR Funding: Astellas Pharma US, Glaxo-SmithKline Author industry relationship disclosures: 12 of 12 Abbot (1) AEterna Zentaris (1) Akros (1) Allergan (3) American Medical Systems (2) Amgen (1) Astellas (10) AstraZeneca (1) Bard (1) Bayer (1) Boehringer Ingelheim (3) Cephalon (1) Coloplast (1) Cook (1) CooperSurgical (1) Eli Lilly (2) Ferring GSK (6) Gynecare (1) Indevus (2) J&J (1) Mankind (1) Medtronic (1) Merck (1) Novartis (3) Novo Nordisk (1) Ortho-McNeil (1) Author industry relationship disclosures: Pfizer (7) Pharmacia (1) Pri Med (1) Reliant (1) Solvay (1) Sanofi-Aventis (1) Schering-Plough (1) Takeda (1) TAP (1) Watson (1) | Design: Prospective cohort, open label, flexible-dose, 14 day washout Intervention: Solifenacin 5–10 mg daily Groups: G1: Solifenacin 5–10 mg daily N at enrollment: G1: 440 N at follow-up (%): G1: 390 (88.4) Age, mean ± SD: G1: 61.4 ± 13.8 Race/ethnicity, n (%): White: G1: 392 (88.9) Women, N (%): G1: 389 (88.2) BMI, kg/m^2^ ± SD: G1: 30.1 ± 7.1 | Inclusion criteria: • Age ≥ 18 • OAB symptoms > 3 months • Treatment with tolterodine ER 4 mg, solifenacin, darifenacin, or trospium × ≥ 4 weeks • Desired change in therapy • ≥ 3 mean UUI episodes/day Exclusion criteria: • Treatment < 4 weeks with tolterodine, solifenacin, darifenacin, or trospium • SUI • MUI with primary stress • UTI • Chronic bladder inflammation • Bladder cancer • Severe constipation • Elevated PVR • Neurological deficit • Renal/hepatic disease • Narrow angle glaucoma • Urinary retention • Gastric retention • Hypersensitivity to drugs • BOO • Women of childbearing age/lactation | Urgency episodes/day, mean change: G1: 6.9 ± 4.4 Incontinence episodes/day, mean ± SD: G1: 3.8 ± 3.6 Voids/day, mean ± SD: G1: 11.3 ± 3.8 Nocturia episodes/day, mean ± SD: G1: 1.9 ± 1.2 PPBC score, mean: G1: 4.2 OAB-q score, mean: Symptom bother: 57.3 Coping: 52.2 Concern: 51.3 Sleep: 50.6 Social Interaction: 77.7 Total score: 56.7 | Urgency episodes/day, mean change ± SD (95% CI): G1: −4.2 ± 4.2 (−4.6, −3.8) G1/BL: P < 0.001 Incontinence episodes/day, mean change ± SD (95% CI): G1: −2.6 ± 3.2 (−3.0, −2.3) G1/BL: P < 0.001 Voids/day, mean change ± SD (95% CI): G1: −2.3 ± 3.2 (−2.6, −2.0) G1/BL: P< 0.001 Nocturia episodes/day, mean change ± SD (95% CI): G1: −0.8 ± 1.0 (−0.9, −0.6) G1/BL: P < 0.001 PPBC score, mean change (95% CI): G1: −1.2 (−1.3, −1.0) G1/BL: P < 0.001 OAB-q score, mean: Symptom bother: 27.8 Coping: 80.1 Concern: 81.1 Sleep: 75.1 Social Interaction: 92.7 Total score: 81.9 G1/BL: P < 0.001 all domains and total score Dry Mouth, n (%): G1: 77 (17.5) Constipation, n (%): G1: 51 (11.6) Blurred vision, n (%): G1: 10 (2.3) UTI, n (%): G1: 19 (4.3) Headache, n (%): G1: 13 (2.9) URI, n (%): G1: 11 (2.5) | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: − Method and blinding: NA Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Chapple et al., 2004 Country and setting: 98 centers – United States, United Kingdom, Poland, Russia, New Zealand, Belgium, Netherlands Enrollment period: NR Funding: Yamanouchi Pharmaceutical Co., Ltd, Tokyo, Japan Author industry relationship disclosures: NR | Design: RCT, double-blind placebo controlled, with 2-wk placebo run-in period Intervention: Tolterodine vs. solifenacin vs. placebo Groups: G1: Tolterodine 2 mg b.i.d. G2: Solifenacin 5 mg qd G3: Solifenacin 10 mg qd G4: Placebo qd N at enrollment: G1: 279 G2: 269 G3: 266 G4: 267 N at follow-up: G1: 250 G2: 266 G3: 264 G4: 253 Female, n (%) G1: 200 (80.0) G2: 188 (71.2) G3: 194 (72.9) G4: 193 (76.3) Age, yrs ± SD: G1: 56.9 +/−12.8 G2: 58.1± 13.4 G3: 57.2 ±13.4 G4: 57.8 ± 13.7 <65 years of age, n (%) G1: 169 (63.5) G2: 172 (65.2) G3: 172 (68.8) G4: 168 (66.4) ≥65 years of age, n (%) G1: 97 (36.5) G2: 92 (34.8) G3: 78 (31.2) G4: 85 (33.6) <75 years of age, n (%) G1: 236 (88.7) G2: 241 (91.3) G3: 233 (93.2) G4: 225 (88.9) ≥75 years of age, n (%) G1: 30 (11.3) G2: 23 (8.7) G3: 17 (16.8) G4: 28 (11.1) Weight, mean kg ± SD G1: 74.8 +/−14.8 G2: 74.6±14.3 G3: 75.5±14.2 G4: 72.6±14.4 Race/ethnicity, n (%): White G1: 261(98.1) G2: 260 (98.5) G3: 247(98.8) G4: 248 (98.0) Black G1: 2 (0.8) G2: 0 G3: 1 (0.4) G4: 1 (0.4) Asian G1: 2 (0.8) G2: 0 G3: 2(0.8) G4: 1 (0.4) Other G1: 1 (0.4) G2: 4 (1.5) G3: 0 G4: 3 (1.2) | Inclusion criteria: • Age ≥ 18 • Symptoms of OAB (including urinary frequency with urgency and/or UI) for ≥ 3 months • ≥ 8 voids per 24 hr • ≥ 3 episodes UUI during 3-day diary period Exclusion criteria: • Clinically significant BOO • Postvoid residual volume >200 mL • Stress predominant factor • Neurological cause for detrusor overactivity • UTI or bladder stones • Previous pelvic irradiation • Malignant disease of pelvic organs • Contraindication to antimuscarinic medication (including narrow-angle glaucoma, urinary or gastric retention) • Non pharma-cological treatment for OAB 2 wks before study • Diabetic neuropathy • Use of drugs intended to treat incontinence • Use of drugs with cholinergic or anticholinergic side-effects • Participation in a clinical trial within 30 days • Childbearing potential, pregnant or nursing or not using reliable contraceptive methods | UUI only, n (%): G1: 142 (56.8) G2: 162 (61.4) G3: 172 (64.7) G4: 177(70.0) MUI, n (%): G1: 90 (36.0) G2: 81 (30.7) G3: 79 (29.7) G4: 59(23.3) No incontinence, n (%): G1: 18 (7.2) G2: 20 (7.6) G3: 15 (5.6) G4: 17 (6.7) UUI episodes/day, mean ± SD: G1: 2.33 ± 2.50 G2: 2.14 ± 2.44 G3: 1.86 ± 1.54 G4: 2.02 ± 2.50 Urgency episodes/day, mean ± SD: G1: 5.77 ± 4.89 G2: 5.82 ± 4.45 G3: 5.45 ± 3.87 G4: 5.30 ± 3.92 Incontinence episodes/day, mean ± SD: G1: 2.64 ± 2.55 G2: 2.59 ± 2.88 G3: 2.32 ± 1.94 G4: 2.71 ± 2.83 Voids/day, mean ± SD: G1: 12.08 ± 3.86 G2: 12.32 ± 3.95 G3: 12.08 ± 3.43 G4: 12.20 ± 4.11 Voided volume (mL), mean ± SD: G1: 149.6 ± 54.6 G2: 147.2 ± 51.2 G3: 147.0 ± 50.3 G4: 143.8 ± 53.6 Time from start of symptoms (months), mean ± SD: G1: 57.4 ± 60.5 G2: 72.6 ± 105.4 G3: 62.9 ± 82.5 G4: 61.0 ± 83.9 Prior drug therapy, n (%): G1: 93 (34.9) G2: 106 (40.1) G3: 77 (30.8) G4: 83 (32.8) Any non drug therapy, n (%): G1: 92 (34.6) G2: 92 (34.8) G3: 88 (35.2) G4: 76 (30.0) | UUI episodes/day, mean change ± SD: G1: −0.91 (2.01) G2: −1.41 (1.74) G3: −1.36 (2.13) G4: −0.62 (1.96) G1/G4: P = 0.239 G2/G4: P = 0.002 G3/G4: P = 0.0028 UUI episodes/day, mean % change: G1: −58 G2: −65 G3: −63 G4: −40 UUI episodes/day, estimated difference vs. tolterodine (95% CI): G2: −0.487 (−0.988, 0.014) G3: −0.436 (−0.921, 0.048) Urgency episodes/day, mean change ± SD: G1: −2.05 ± 3.58 G2: −2.85 ± 3.74 G3: −3.07 ± 3.90 G4: −1.41 ± 3.67 G1/G4: P = 0.0511 G2/G4: P < 0.001 G3/G4: P < 0.001 Urgency episodes/day, mean % change: G1: −38 G2: −55 G3: −52 G4: −33 Urgency episodes/day, estimated difference vs. tolterodine (95% CI): G2: −0.791 (−14.34, −0.148) G3: −1.015 (−1.659, −0.370) Incontinence episodes/day, mean change ± SD: G1: −1.42 ± 1.82 G2: −1.45 ± 2.24 G3: −1.14 ± 2.15 G4: −0.76 ± 2.26 G1/G4: P = 0.1122 G2/G4: P = 0.008 G3/G4: P = 0.0038 Incontinence episodes/24 h Δ from baseline, %: G1: −59 G2: −47 G3: −59 G4: −29 Incontinence episodes/day, estimated difference vs. tolterodine (95% CI): G2: −0.276 (−0.761, 0.208) G3: −0.316 (−0.786, 0.154) Voids/day, mean change ± SD: G1: −1.88 ± 3.00 G2: −2.19 ± 2.87 G3: −2.61 ± 3.24 G4: −1.20 ± 3.26 G1/G4: P = 0.0145 G2/G4: P = 0.003 G3/G4: P < 0.001 Voids/day, mean % change: G1: −15 G2: −20 G3: −17 G4: −18 Voids/day, estimated difference vs. tolterodine (95% CI): G2: −0.312 (−0.844, 0.219) G3: −0.737 (−1.269, −0.204) Voided volume (mL), mean change ± SD: G1: 24.4 ± 49.2 G2: 32.9 ± 47.7 G3: 39.2 ± 50.4 G4: 07.4 ± 36.3 G1/G4: P < 0.001 G2/G4: P < 0.001 G3/G4: P < 0.001 Voided volume (mL), mean % change: G1: 20 G2: 25 G3: 29 G4: 9 Voided volume (mL), estimated difference vs. tolterodine (95% CI): G2: 8.4 (0.496, 16.34) G3: 14.8 (6.855, 22.72) Discontinued due to AEs, n (%): G1: 5 (1.9) G2: 9 (3.2) G3: 7 (2.6) G4: 10 (3.7) Dry mouth, n (%): G1: 49 (18.6) G2: 39 (14.0) G3: 57 (21.3) G4: 13 (4.9) Constipation, n (%): G1: 7 (2.6) G2: 20 (7.2) G2: 21 (7.8) G4: 5 (1.9) Blurred Vision, n (%): G1: 4 (1.5) G2: 10 (3.6) G3: 15 (5.6) G4: 7 (2.6) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: ++ Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Chapple et al., 2005^*^ Chapple, Fianu-Jonsson et al., 2007† Country and setting: European, Multicenter Enrollment period: May 2003 to October 2004 Funding: Yamanouchi (now Astellas) Author industry relationship disclosures: NR^*^ 1 of 9† Astellas (1) Novartis (1) Pfizer (1) Schwartz (1) UCB (1) | Design: RCT Intervention: Solifenacin 5 mg vs. tolterodine ER 4 mg Groups: G1: Solifenacin 5mg G2: Tolterodine ER 4mg G1a: G1 who elected not to increase dose at 4 weeks G2a: G2 who elected not to increase dose at 4 weeks N at enrollment: G1: 578 G2: 599 N at follow-up: G1a: 297 G2a: 267 Age, mean: G1: 56.5 G2: 56.4 G1a: 56.5 G2a: 56.9 Race/ethnicity, %: White: G1: 99.3 G2: 99.5 G1a: 99.3 G2a: 99.3 Women, %: G1: 85.3 G2: 88.3 G1a: 87.5 G2a: 87.1 | Inclusion criteria: • Age ≥ 18 • OAB symptoms for ≥ 3 months • Outpatient treatment • ≥ 8 voids/day • ≥ 1 incontinence episode/day or ≥ 1 urgency episode/day Exclusion criteria: NR | UUI episodes/day, mean ± SD:^*^ G1: 2.31 ± 2.35 G2: 2.12 ± 2.14 UUI episodes/day, mean:† G1a: 1.97 G2a: 1.66 Urgency episodes/day, mean ± SD:^*^ G1: 6.01 ± 4.66 G2: 5.84 ± 4.12 Urgency episodes/day, mean:† G1a: 5.67 G2a: 5.30 Incontinence episodes/day, mean ± SD:^*^ G1: 2.77 ± 2.65 G2: 2.55 ± 2.37 Incontinence episodes/day, mean:† G1a: 2.32 G2a: 2.01 Voids/day, mean ± SD:^*^ G1: 11.78 ± 3.58 G2: 11.66 ± 3.25 Voids/day, mean:† G1: 11.10 G2: 11.36 Nocturia, episodes/day, mean ± SD:^*^ G1: 2.02 ± 1.33 G2: 1.92 ± 1.22 Nocturia, episodes/day, mean:† G1a: 1.83 G2a: 1.84 | UUI episodes/day, 4 wks, mean change:† G1: −1.22 G2: −0.91 P = NS UUI episodes/day, 12 wks, mean change:^*^ G1: −1.42 G2: −0.83 P = 0.001 UUI episodes/day, 12 wks, mean change:† G1a: −1.46 G2a: −1.03 Urgency episodes/day, 4 wks, mean change:† G1: −1.98 G2: −1.67 P = NS Urgency episodes/day, 12 wks, mean change:^*^ G1: −2.85 G2: −2.42 P = 0.035 Urgency episodes/day, 12 wks, mean change:† G1a: −3.08 G2a: −2.62 Incontinence episodes/day, 4 wks, mean change:† G1: −1.30 G2: −0.90 P = 0.0181 Incontinence episodes/day, 12 wks, mean change:^*^ G1: −1.60 G2: −1.11 P = 0.006 Incontinence episodes/day, 12 wks, mean change:† G1a: −1.56 G2a: −1.23 Voids/day, 4 wks, mean change:† G1: −1.71 G2: −1.47 P = NS Voids/day, 12 wks, mean change:^*^ G1: −2.45 G2: −2.24 P = 0.004 for non-inferiority Voids/day, 12 wks, mean change:† G1a: −2.47 G2a: −2.49 Nocturia, episodes/day, 4 wks, mean change:† G1: −0.51 G2: −0.44 P = NS Nocturia, episodes/day, 12 wks, mean change:^*^ G1: −0.71 G2: −0.63 P = NS Nocturia episodes/day, 12 wks, mean change:† G1a: −0.72 G2a: −0.69 Perception of bladder condition, 4 wks, mean change:† G1: −0.96 G2: −0.88 P = NS Perception of bladder condition, 12 wks, mean change:^*^ G1: −1.51 G2: −1.33 P < 0.0061 Perception of bladder condition, 12 wks, mean change:† G1a: −1.72 G2a: −1.62 Pad use, 4 wks, mean change:† G1: −1.21 G2: −0.80 P = 0.0089 Pad use, 12 wks, mean change:^*^ G1: −1.72 G2: −1.19 P < 0.0023 Pad use, 12 wks, mean change:† G1a: −1.55 G2a: −1.40 Dry rate, 4 wks, mean % change:† G1: 39 G2: 34 P = NS Dry rate, 12 wks, mean % change:† G1a: 65.4 G2a: 58.3 P = NS Voided volume (mL), 12 wks, mean change:* G1: 38 G2: 31 P = 0.010 Voided volume (mL), 12 wks, mean change:† G1a: 39.95 G2a: 37.84 Dry mouth, mild, %:*† G1: 17.5 G2: 14.8 G1a: 6.5 G2a: 5.0 Dry mouth, moderate, %:*† G1: 10.8 G2: 7.7 G1a: 10.4 G2a: 7.0 Dry mouth, severe, %:*† G1: 1.7 G2: 1.5 G1a: 0.7 G2a: 2.1 Constipation, mild, %:*† G1: 3.2 G2: 1.3 G1a: 2.0 G2a: 1.0 Constipation, moderate, %:*† G1: 2.7 G2: 1.0 G1a: 1.7 G2a: 1.4 Constipation, severe, %:*† G1: 0.5 G2: 0.2 G1a: 0.3 G2a: 0.0 Blurred vision, mild, %:*† G1: 0.7 G2: 0.7 G1a: 0.3 G2a: 0.7 Blurred vision, moderate, %:*† G1: 0.0 G2: 1.0 G1a: 0.0 G2a: 1.7 Blurred vision, severe, %:*† G1: 0.0 G2: 0.0 G1a: 0.0 G2a: 0.0 | Quality: Overall quality score: good INTERNAL VALIDITY: good Randomization: + Masking: + Pt selection criteria: + Loss to followup: ++ Drop-out rates: ++ Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Chapple, Van Kerrebroeck et al., 2007 Country and setting: Multicenter study in Europe, Africa, and Oceania (academic and private), 150 sites in 19 countries Enrollment period: NR Funding: Schwarz BioSciences GmbH, Pfizer Inc. Author conflicts of interest: 9 of 9: Astellas (Yamanouchi) (2) Eli-Lilly (1) Ferring (1) GlaxoSmithKline (1) Novartis (3) Pfizer (5) Schwarz (4) UCB (1) | Design: RCT Intervention: Fesoterodine (8 mg or 4 mg) vs. tolterodine ER 4 mg Groups: G1: Tolterodine ER 4mg G2: Fesoterodine 8mg G3: Fesoterodine 4mg G4: Placebo N at enrollment: G1: 290 G2: 288 G3: 272 G4: 285 N at follow-up: G1: 253 G2: 252 G3: 231 G4: 252 Age, mean ± SD: G1: 57.7 ± 14.6 G2: 55.6 ± 14.1 G3: 57.1 ± 13.2 G4: 56.0 ± 13.7 Women, %: G1: 78 G2: 82 G3: 81 G4: 81 Race/ethnicity, %: White: G1: 98 G2: 98 G3: 96 G4: 98 Black: G1: 0 G2: 1 G3: 0 G4: <1 Asian: G1: 2 G2: 1 G3: 2 G4: 2 Other: G1: <1 G2: 0 G3: 3 G4: <1 BMI, kg/m^2^ ± SD: G1: 27.5 ± 5.2 G2: 27.1 ± 5.2 G3: 27.5 ± 5.5 G4: 27.2 ± 5.2 | Inclusion criteria: • OAB symptoms with urinary urgency for ≥ 6 mos • Age ≥ 18 • ≥ 8 voids per day • ≥ 6 urgency episodes or ≥ 3 UUI episodes/day • At least moderate problems recorded via a Likert scale • Negative pregnancy test • Adequate contraception Exclusion criteria: • SUI • Bladder stones • Interstitial cystitis • Urothelial tumors • Grade III or higher pelvic prolapse • BOO • Polyuria (>3L/d) • UTIs • PVR urine volume >100mL • Use of antimuscarinic ≤ 2 weeks • Treatment with electrostimulation ≤ 4 weeks • Neurological disease • Clinically relevant cardiac arrhythmia • Unstable angina • QTcB interval > 500ms | UUI episodes/day, mean ± SD: G1: 3.8 ± 3.1 G2: 3.7 ± 3.0 G3: 3.8 ± 3.1 G4: 3.7 ± 3.1 Urgency episodes/day mean ± SD: G1: 11.0 ± 3.4 G2: 11.5 ± 4.2 G3: 11.0 ± 3.4 G4: 11.4 ± 4.0 Incontinence, %: G1: 79 G2: 81 G3: 75 G4: 76 Continent days/wk, mean ± SD: G1: 0.6 ± 1.3 G2: 0.6 ± 1.3 G3: 0.8 ± 1.6 G4: 0.8 ± 1.5 Voids/day, mean ± SD: G1: 11.5 ± 2.9 G2: 11.9 ± 3.8 G3: 11.6 ± 3.2 G4: 12.0 ± 3.7 Daytime voids/day, mean ± SD: G1: 2.0 ± 1.2 G2: 2.0 ± 1.6 G3: 1.9 ± 1.3 G4: 1.8 ± 1.2 Duration of OAB symptoms (yrs), mean ± SD: G1: 8.7 ± 10.1 G2: 7.6 ± 8.4 G3: 9.0 ± 11.2 G4: 7.9 ± 9.6 Previous drug treatment, n (%): G1: 135 (47) G2: 118 (41) G3: 102 (38) G4: 112 (40) Voided volume (mL), mean ± SD: G1: 154.3 ± 52.9 G2: 153.9 ± 56.9 G3: 160.0 ± 59.5 G4: 150.2 ± 52.0 | UUI episodes/day, LS mean change (SE): G1: −1.74 (0.16) G2: −2.22 (0.16) G3: −1.95 (0.17) G4: −1.14 (0.16) G1/G4: P = 0.008 G2/G4: P < 0.001 G3/G4: P = 0.001 UUI episodes/day, median % change: G1: −70.0 G2: −87.5 G3: −80.0 G4: −50.0 G1/G4: P = 0.105 G2/G4: P < 0.001 G3/G4: P = 0.001 Urgency episodes/day mean change (SE): G1: −2.03 (0.19) G2: −2.36 (0.20) G3: −1.88 (0.20) G4: −1.07 (0.19) G1/G4: P < 0.001 G2/G4: P < 0.001 G3/G4: P = 0.003 Urgency episodes/day median change, %: G1: −16.0 G2: −19.1 G3: −17.6 G4: −11.1 G1/G4: P = 0.004 G2/G4: P < 0.001 G3/G4: P = 0.002 Continent days/wk mean change (SE): G1: 2.48 (0.20) G2: 3.32 (0.19) G3: 2.84 (0.21) G4: 2.07 (0.20) G1/G4: P = 0.139 G2/G4: P < 0.001 G3/G4: P = 0.007 Voids/day, LS mean change (SE): G1: −1.73 (0.16) G2: −1.88 (0.16) G3: −1.76 (0.17) G4: −0.95 (0.16) G1/G4: P = 0.001 G2/G4: P < 0.001 G3/G4: P < 0.001 Voids/day, median % change: G1: −13.8 G2: −18.6 G3: −16.7 G4: −11.1 G1/G4: P = 0.005 G2/G4: P < 0.001 G3/G4: P < 0.001 Daytime voids/day, LS mean change (SE): G1: −0.40 (0.06) G2: −0.39 (0.06) G3: −0.39 (0.06) G4: −0.32 (0.06) Daytime voids/day, median % change: G1: −25.0 G2: −23.1 G3: −28.6 G4: −26.8 Treatment Response, % yes: G1: 72 G2: 79 G3: 75 G4: 53 G1/G4: P < 0.001 G2/G4: P < 0.001 G3/G4: P < 0.001 Maximum voided volume, mean change (SE): G1: 23.64 (3.31) G2: 33.62 (3.35) G3:27.72 (3.41) G4: 9.37 (3.33) G1/G4: (P = 0.003) G2/G4: (P <0.001) G3/G4: (P = 0.001) Adverse events, n (%): G1: 144 (50) G2: 167 (58) G3: 135 (50) G4: 107 (38) Dry mouth, n (%): G1: 49 (16.9) G2: 97 (33.8) G3: 59 (21.7) G4: 20 (7.1) Constipation, n (%): G1: 8 (2.8) G2: 13 (4.5) G3: 9 (3.3) G4: 4 (1.4) Headache, n (%): G1: 14 (4.8) G2: 7 (2.4) G3: 12 (4.4) G4: 14 (4.9) Dry eye, n (%): G1: 1 (<1) G2: 12 (4.2) G3: 6 (2.2) G4: 0 Nasopharyngitis, n (%): G1: 10 (3.4) G2: 5 (1.7) G3: 8 (2.9) G4: 7 (2.5) Fatigue, n (%): G1: 10 (3.4) G2: 1 (<1) G3: 1 (<1) G4: 1 (<1) Influenza, n (%): G1: 2 (<1) G2: 2 (<1) G3: 9 (3.3) G4: 6 (2.1) Dry throat, n (%): G1: 3 (1) G2: 8 (2.8) G3: 1 (<1) G4: 0 Dizziness, n (%): G1: 4 (1.4) G2: 3 (1.0) G3: 4 (1.5) G4: 7 (2.5) Alanine aminotransferase, n (%): G1: 0 G2: 6 (2.1) G3: 2 (<1) G4: 1 (<1) Nausea, n (%): G1: 6 (2.1) G2: 4 (1.4) G3: 1 (<1) G4: 1 (<1) Mean change in heart rate (bpm): G1: 2.89 G2: 3.9 G3: 3.3 G4: 0.8 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: − Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Chapple, DuBeau et al., 2007 Country and setting: US, Poland, South Africa, Hungary, Sweden, United Kingdom, Germany; 73 centers Enrollment period: NR Funding: Novartis Author industry relationship disclosures: NR | Design: RCT Intervention: Darifenacin 7.5 mg qd versus placebo × 12 weeks, with optional up-titration offered (to 15 mg qd) after 2 weeks of treatment Groups: G1: Darifenacin G2: Placebo N at enrollment: G1: 266 G2: 133 N at follow-up (%): G1: 244 (91.7) G2: 117 (87.3) Age, mean ± SD (range): G1: 72 ± 5 (64–89) G2: 73 ± 5 (64–87) Women, n (%): G1: 206 (77.4) G2: 100 (75.2) Race/ethnicity: NR Follow-up: 12 weeks | Inclusion criteria: • Age ≥ 65 • OAB sx for ≥ 6 months • Capable of independent toileting • Able to complete the diary independently • Completed at least 5 days of the 7-day diary during the baseline period • ≥ 1 UUI episodes/day • ≥ 10 micturitions/day Exclusion criteria: • Treatment w/drugs known to effect urinary bladder function or the external urethral sphincter • Total urinary volume ≥ 3L • Mean voided volume > 300 ml • Clinically significant SUI or BOO • PVR > 100mL by ultrasound • Women with marked cystocele or other clinically significant Stage 3 or Stage 4 pelvic prolapsed • Participated in a bladder-training program or received electrical stimulation therapy w/in 3 mos of screening • Serious or intermittent UTI • Clinically significant congenital or acquired disorder of the urinary tract • Any urinary bladder dysfunction other than OAB • Hx of chronic pain syndrome of the lower urinary tract Other significant medical conditions that made participant unfit (cognitive impairment, uncontrolled severe HTN, uncontrolled severe heart failure, recent MI, uncontrolled thyroid disease | UUI episodes/week, median (range): G1: 19.8 (4.0–142.0) G2: 21.0 (7.0–155.4) Urgency episodes/day, median (range): G1: 7.6 (1.0–24.4) G2: 7.4 (1.3–22.2) Voids/day, median (range): G1: 11.8 (7.1–25.1) G2: 12.0 (7.6–27.6) | UUI episodes/week, median change (% change): G1: −14.0 (−88.6) G2: −13.0 (−77.9) UUI episodes/week, median change (95% CI): G1/G2: −1.0 (−2.83, 1) P = 0.328 Urgency episodes/day, median change (% change): G1: −3.3 (−69.6) G2: −3.1 (−55.5) Urgency episodes/day, median change (% change): G1/G2: −0.5 (−1.2, 0.2) P = 0.174 Voids/day, median change (% change): G1: −3.0 (−25.3) G2: −2.2 (−18.5) Voids/day, median change (95% CI): G1/G2: −0.7 (−1.1, −0.2) P = 0.006 OAB-q, total score, mean change: G1: 22.9 G2: 16.8 P < 0.001 OAB-q, symptom severity score, mean change: G1: −27.9 G2: −20.7 P < 0.001 OAB-q, coping score, mean change: G1: 27.4 G2: 19.2 P < 0.001 OAB-q, concern score, mean change: G1: 26.5 G2: 18.6 P < 0.001 OAB-q, sleep score, mean change: G1: 21.1 G2: 16.8 P = 0.015 OAB-q, social score, mean change: G1: 12.5 G2: 10.4 P = 0.047 PVR (mL), wk 12, mean change (95% CI): G1: 11.9 (1.7, 22.1) G2: 17.3 (−18.1, 52.8) P = NS Adverse Event, n (%) G1: 149 (56.0) G2: 60 (45.1) AEs attributed to treatment, n (%) G1: 99 (37.2) G2: 24 (18.0) Dry mouth, n (%) G1: 59 (22.2) G2: 5 (3.8) Constipation, n (%) G1: 41 (15.4) G2: 11 (8.3) Discontinued due to AEs, n (%) G1: 4 (1.6) G2: 1 (0.8) | Quality: Overall quality score: good INTERNAL VALIDITY: good Randomization: + Method and blinding: + Pt selection criteria: + Loss to followup: ++ Drop-out rates: + Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Chapple et al., 2008 Country and setting: European, multicenter (academic and private) Enrollment period: NR Funding: Pfizer, Schwarz BioSciences Author industry relationship disclosures: 4 of 5 Pfizer (4) | Design: Multicenter randomized placebo-controlled Intervention: Tolterodine 4 mg ER vs. fesoterodine 8 mg Groups: G1: Tolterodine ER 4mg G2: Fesoterodine 8mg G3: Placebo N at enrollment: G1: 290 G2: 287 G3: 283 Age, mean ± SD: Total: 57 ± 14 Race/ethnicity, %: White: Total: >95 Women, %: Total: 80 Follow-up: 12 weeks | Inclusion criteria: • Age ≥ 18 • OAB sx w/urinary urgency for ≥6 mos • ≥ 8 voids/day • ≥ 6 urgency episodes or ≥ 3 UUI episodes/day • At least moderate problems recorded via a Likert scale • Negative pregnancy test • Adequate contraception throughout trial Exclusion criteria: • LUT pathology: SI, bladder stones, interstitial cystitis, urothelial tumors • Grade III or higher pelvic prolapsed • Bladder-outlet obstruction • Polyuria (>3L/d) • Symptomatic or recurrent UTIs • PVR urine volume >100 mL • Antimuscarinic agent w/in 2 wks • Electrostimulation for bladder training in prior 4 wks • Active UTI • Underlying neurological dz • Clinically relevant cardiac arrhythmia • Unstable angina • QTcB interval > 500ms | Time since first diagnosis or onset of OAB (years), mean: Total: 8–9 Incontinent at BL, n: G1: 213 G2: 217 G3: 203 | KHQ severity score, mean change: G1: −12.6 G2: −14.0 G3: −9.0 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ severity score, patients incontinent at BL, mean change: G1: −14.9 G2: −15.8 G3: −10.8 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ emotions score, mean change: G1: −16.3 G2: −17.4 G3: −10.1 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ emotions score, patients incontinent at BL, mean change: G1: −17.3 G2: −18.6 G3: −11.3 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ role limitations score, mean change: G1: −22.1 G2: −21.7 G3: −11.8 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ role limitations score, patients incontinent at BL, mean change: G1: −23.2 G2: −23.7 G3: −12.4 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ physical limitations score, mean change: G1: −19.7 G2: −21.7 G3: −11.4 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ Physical limitations score, patients incontinent at BL, mean change: G1: −20.5 G2: −23.3 G3: −11.1 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ social limitations score, mean change: G1: −14.1 G2: −15.4 G3: −8.7 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ social limitations score, patients incontinent at BL, mean change: G1: −15.7 G2: −16.2 G3: −9.5 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ sleep/energy score, mean change: G1: −11.7G2: −13.6 G3: −9.6 G1/G3: P = NS G2/G3: P < 0.05 KHQ sleep/energy score, patients incontinent at BL, mean change: G1: −12.5 G2: −15.3 G3: −10.4 G1/G3: P = NS G2/G3: P < 0.05 KHQ personal relationship score, mean change: G1: −10.4 G2: −11.9 G3: −6.2 G1/G3: P = NS G2/G3: P < 0.05 KHQ personal relationship score, patients incontinent at BL, mean change: G1: −12.7 G2: −12.3 G3: −6.8 G1/G3: P < 0.05 G2/G3: P = NS KHQ incontinence impact score, mean change: G1: −23.3 G2: −24.6 G3: −16.1 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ incontinence impact score, patients incontinent at BL, mean change: G1: −23.8 G2: −26.5 G3: −17.7 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ general health score, mean change: G1: −4.3 G2: −4.0 G3: −3.8 G1/G3: P = NS G2/G3: P = NS KHQ general health score, patients incontinent at BL, mean change: G1: −4.3 G2: −4.5 G3: −5.5 G1/G3: P = NS G2/G3: P = NS ICIQ-SF total score, mean: G1: −3.95 G2: −4.41 G3: −2.55 G1/G3: P < 0.05 G2/G3: P < 0.05 ICIQ-SF total score, patients incontinent at BL, mean: G1: −4.56 G2: −5.29 G3: −3.12 G1/G3: P < 0.05 G2/G3: P < 0.05 Major improvement in severity of bladder-related problems, %: G1: 34 G2: 39 G3: 25 G1/G3: P = 0.01 G2/G3: P = 0.01 Dry mouth, n (%): G1: 49 (17) G2: 97 (34) G3: 20 (7) Constipation, n (%): G1: 8 (3) G2: 13 (5) G3: 4 (1) Nasopharyngitis, n (%): G1: 10 (3) G2: 5 (2) G3: 7 (3) Dry eye, n (%): G1: 1 (1) G2: 12 (4) G3: 0 (0) Nausea, n (%): G1: 6 (2) G2: 4 (1) G3: 1 (1) Fatigue, n (%): G1: 10 (3) G2: 1 (1) G3: 1 (1) Dry throat, n (%): G1: 3 (1) G2: 8 (3) G3: 0 (0) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Method and blinding: + Pt selection criteria: + Loss to followup: NR Drop-out rates: NR Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Choo et al., 2008 Country and setting: Korea, Academic hospital Enrollment period: July 2005 to March 2006 Funding: NR Author industry relationship disclosures: None | Design: Prospective cohort Intervention: Tolterodine ER 4 mg qd x 12 wks Groups: NA N at enrollment: 60 N at follow-up: 56 Women, %: 100 Age, mean ± SD: 54.8 ± 11.5 Race/ethnicity: NR | Inclusion criteria: • Age ≥ 18 • OAB for ≥ 3 mos • ≥ 8 frequency episodes/d and ≥ 2 urgency episodes/d Exclusion criteria: • Total 24-h micturition volume > 3L • PVR > 30% of voided volume or ≥ 150 mL • Stress UI • Hx of urinary retention • Active UTI • Indwelling catheter • Intermittent self-catheterisation • Neurological dz • Any condition for which antimuscarinic agents are contraindicated | UUI episodes/ day, mean ± SD: 1.4 ± 2.7 UUI episodes/ day, mean ± SD: PGA < 80%: 2.4 ± 3.4 PGA ≥ 80%: 2.9 ± 4.1 Urgency episodes/day, mean ± SD: 9.6 ± 6.8 Urgency episodes/day, mean ± SD: PGA < 60%: 12.6 ± 7.7 PGA ≥ 60%: 7.1 ± 4.9 P < 0.01 Total of all urgency scales/ day, mean ± SD: 94.4 ± 43.0 Voids/day, mean ± SD: 12.6 ± 5.3 Voids/day, mean ± SD: PGA < 60%: 14.9 ± 6.2 PGA ≥ 60%: 10.5 ± 2.9 P < 0.01 Nocturia episodes/day, mean ± SD: 1.6 ± 0.9 Nocturia episodes/day, mean ± SD: PGA < 50%: 1.9 ± 0.8 PGA ≥ 50%: 1.6 ± 0.7 Most troublesome symptoms, n (%): UUI: 9 (16.1) Urgency: 6 (10.7) Frequency: 28 (50) Nocturia: 10 (17.9) Tenesmus: 3 (5.4) Voided volume, (mL), mean ± SD: 157.0 ± 70.3 | UUI episodes /day, 12 wks, mean ± SD: 0.4 ± 0.9 P < 0.01 UUI severity, 12 wks, median % change (95% CI): −71 (−76.8, −39.2) UUI, PGA median rate, % (95% CI): 80 (34.2, 80.0) UUI episodes /day, 12 wks, mean change ± SD: PGA < 80%: −0.9 ± 1.6 PGA ≥ 80%: −2.8 ± 4.3 UUI, PPBC, mean change ± SD: PGA < 80%: −1.6 ± 1.1 PGA ≥ 80%: −2.2 ± 1.5 UUI, GII, %: PGA < 80%: No: 1 (11.1) Little: 5 (55.6) Much: 3 (33.3) PGA ≥ 80%: No: 0 (0) Little: 4 (40.0) Much: 6 (60.0) UUI, continue treatment, n (%): PGA < 80%: 5 (55.6) PGA ≥ 80%: 8 (80.0) Urgency episodes /day, 12 wks, mean ± SD: 5.4 ± 4.5 P < 0.01 Urgency severity, 12 wks, median % change (95% CI): −55 (−60.4, −40.1) Total of all urgency scales/ day, 12 wks, mean ± SD: 66.3 ± 31.2 P < 0.01 Urgency, PGA median rate, % (95% CI): 60 (46.2, 64.9) Urgency episodes /day, 12 wks, mean change ± SD: PGA < 60%: −4.2 ± 6.8 PGA ≥ 60%: −4.3 ± 4.7 P < 0.01 Urgency, PPBC, mean change ± SD: PGA < 60%: −1.5 ± 1.0 PGA ≥ 60%: −2.3 ± 1.1 P < 0.01 Urgency, GII, %: PGA < 60%: No: 4 (16.0) Little: 15 (60.0) Much: 6 (24.0) P < 0.01 PGA ≥ 60%: No: 0 (0) Little: 7 (22.6) Much: 24 (77.4) P < 0.01 Urgency, pts want to continue treatment, n (%): PGA < 60%: 16 (64.0) PGA ≥ 60%: 25 (80.6) Voids/day, 12 wks, mean ± SD: 9.9 ± 4.2 P < 0.01 Frequency severity, 12 wks, median % change (95% CI): −45 (−54.4, −36.2) Frequency, PGA median rate, % (95% CI): 60 (46.9, 63.6) Voids/day, 12 wks, mean change ± SD: PGA < 60%: −2.6 ± 2.9 PGA ≥ 60%: −2.7 ± 2.2 P < 0.01 Frequency, PPBC, mean change ± SD: PGA < 60%: −1.4 ± 1.1 PGA ≥ 60%: −2.4 ± 1.0 P < 0.01 Frequency, GII, %: PGA < 60%: No: 4 (14.8) Little: 16 (59.3) Much: 7 (25.9) P < 0.01 PGA ≥ 60%: No: 0 (0) Little: 6 (20.7) Much: 23 (79.3) P < 0.01 Frequency, continue treatment, n(%): PGA < 60%: 18 (66.7) PGA ≥ 60%: 23 (79.3) Nocturia episodes/day, 12 wks, mean ± SD: 0.9 ± 0.8 P < 0.01 Nocturia severity, 12 wks, median % change (95% CI): −52 (−59.7, −40.2) Nocturia, PGA median rate, % (95% CI): 50 (39.4, 57.6) Nocturia episodes/day, 12 wks, mean change ± SD: PGA < 50%: −0.6 ± 1.1 PGA ≥ 50%: −1.4 ± 0.9 Nocturia, PPBC, mean change ± SD: PGA < 50%: −1.3 ± 0.9 PGA ≥ 50%: −2.3 ± 1.1 P < 0.01 Nocturia, GII, %: PGA < 50%: No: 4 (20.0) Little: 13 (65.0) Much: 3 (15.0) P < 0.01 PGA ≥ 50%: No: 0 (0) Little: 6 (20.7) Much: 23 (79.3) P < 0.01 Nocturia, pts want to continue treatment, n (%): PGA < 50%: 9 (45.0) PGA ≥ 50%: 26 (89.7) P < 0.01 Nocturia severity, 12 wks, median % change (95% CI): −52 (−59.7, −40.2) Tenesmus severity, 12 wks, median % change (95% CI): −26 (−50.4, −16.9) Tenesmus, PGA median rate, % (95% CI): 30 (25.4, 52.2) Tenesmus, PPBC, mean change ± SD: PGA < 30%: −1.4 ± 0.9 PGA ≥ 30%: −2.1 ± 1.1 Tenesmus, GII, %: PGA < 30%: No: 2 (15.4) Little: 9 (69.2) Much: 2 (15.4) P < 0.01 PGA ≥ 30%: No: 0 (0) Little: 5 (31.3) Much: 11 (68.8) P < 0.01 Tenesmus, pts want to continue treatment, n (%): PGA < 30%: 8 (61.5) PGA ≥ 30%: 14 (87.5) Most troublesome symptom severity, median % change: UUI: −64.5 Urgency: −32 Frequency: −42.5 Nocturia: −56.5 Voided volume (mL), 12 wks, mean ± SD: 189.3 ± 111.5 P = 0.05 Dry mouth, n (%): 13 (21.7) Constipation/indigestion, n (%): 6 (10) Headache, n (%): 3 (5) UTI, n (%): 2 (3.3) Peripheral oedema, n (%): 1 (1.7) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: - Methods and blinding: - Pt selection criteria: + Loss to followup: ++ Drop-out rates: ++ Power calculation: + Statistical issues: - EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: + Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Colombo et al., 1995 Country and setting: Italy; Setting Enrollment period: May 1990 to March 1993 Funding: NR Author industry relationship disclosures: NR | Design: RCT, Computer generated random assignment Intervention: Oxybutynin vs. Bladder training for 6 weeks Groups: G1: Oxybutynin, 3 daily doses of 5 mg each for 6 weeks (dose reduced to half if substantial AEs) G2: Bladder training N at enrollment: G1: 42 G2: 39 N at 6 wk follow-up: G1: 38 G2: 37 N at 6 mo follow-up: G1: 28 G2: 27 Age, yrs ± SD: G1: 48 (31 – 65) G2: 49 (24 – 65) Race/ethnicity: NR Women, N (%): G1: 42 (100) G2: 39 (100) Postmenopausal n (%): G1: 16 (38) G2: 20 (51) | Inclusion criteria: • Socially embarrassing (severe) urinary urge incontinence • On cystometry: detrusor instability, or low-compliance bladder (LCB), or sensory bladder Exclusion criteria: • Stable bladder at cystometry • Neurologic disease • Detrusor hyperreflexia • Age greater than 65 y • Coexisting genuine SUI • Genital prolapse • Postvoid residual volume >50mL • Previous gynecologic or urogynecologic surgery • Prior use of any drug to treat UUI • Urethral diverticula • Fistulas • Urinary tract neoplasia Cystitis • Bladder stones • Previous pelvic radiotherapy | Detrusor instability, n (%): G1: 14 (37) G2: 13 (35) Low compliance bladder, n (%): G1: 9 (24) G2: 8 (22) Sensory bladder, n (%): G1: 15 (39) G2: 16 (43) Daily UUI episodes, range 9 – 17 Diurnal frequency, n (%): G1: 32 (84) G2: 29 (78) Nocturia, n (%): G1: 11 (29) G2: 18 (49) Volume at first desire (mL): G1: 120 ± 59 G2: 134 ± 61 Volume at very strong desire (mL): G1: 317 ± 92 G2: 332 ± 87> | Clinically cured overall, n (%): G1: 28 (74) G2: 27 (73) Cured among DI, (%): G1: 13 (93) G2: 8 (62) P = 0.07 Cured among LCB: G1: 6 (67) G2: 6 (75) P = 0.56 Cured among sensory bladder: G1: 9 (60) G2: 13 (81) P = 0.18 Cured among 18 G1 patients requiring dosage halving: 12 (67%) Diurnal frequency resolved, n (%): G1: 18 (56) G2: 20 (69) Nocturia resolved n (%): G1: 3 (27) G2: 11 (61) Volume at first desire (mL), mean ± SD: G1: 179 ± 32 P = .0009 G2: 178 ± 49 P = .001 Volume at very strong desire (mL) mean ± SD: G1: 408 ± 76 P = .00001 G2: 403 ± 69 P = .0002 Patients still cured at 6 mos,n: G1: 16 G2: 26 Patients still cured at 6 mos among DI, n: G1: 8 G2: 8 Patients still cured at 6 mos among LCB, n: G1: 4 G2: 6 Patients still cured at 6 mos among sensory bladder, n: G1: 4 G2: 12 Treatment discontinued in 6 cases: G1: 4 (3 cases of severe dry mouth, 1 case of previously unknown glaucoma) G2: 2 (treatment was time consuming) Other adverse effects G1: 18 (47%) with AE requiring halving of dosage: -dry mouth (n=15) -constipation (n=6) -nausea (n=5) -dizziness (n=2) - decrease in visual acuity (n=1) - tachycardia (n=1) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: + Masking: − Pt selection criteria: + Loss to followup: ++ Drop-out rates: + Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: - Measurement methods: + Measurement reliability: - Intervention description: +
Author: Davila, et al., 2001 Country and setting: US, Specialty treatment centers Enrollment period: 6 weeks Funding: Watson Laboratories, Inc Author industry relationship disclosures: 2 of 3 Pharmadigm (1) Watson Laboratories (2) | Design: RCT Intervention: Transdermal Oxybutynin vs. Oral Oxybutynin 2 week washout Groups: G1: Transdermal OXY 1.3mg/day G2: OXY 2.5mg b.i.d./t.i.d. N at enrollment: G1: 38 G2: 38 N at follow-up: G1: 38 G2: 36 Women, n (%): G1: 33 (87) G2: 37 (97) Age, mean ± SD: G1: 64 ± 15 G2: 63 ± 13 Race/ethnicity, n, (%): White: 72 (95) Black: 4 (5) | Inclusion criteria: • Age ≥ 18 • History of UUI or MUI with predominant urge symptoms • ≥ 3 episodes UI/day with ≥ 30% increase in UUI episodes/day during 2 week washout • Diagnosis of motor urge incontinence • Improvement during ≥ 6 wks with oral oxybutynin • UDS confirmed motor urge incontinence Exclusion criteria: • Allergy to oxybutynin • Intolerability of transdermal system • Pregnancy or breastfeeding • Overflow incontinence secondary to underactive or non-contractile detrusor • BOO • Impaired bladder compliance including tonic increase in pressure> 15 cm H_2_O during filling cystometry • Medical conditions or drug therapies that could cause incontinence • Medical conditions that could be worsened by oxybutynin | Incontinence episodes/day, mean ± SD: G1: 7.2 ± 4.5 G2: 7.2 ± 4.1 Bladder volume (mL), first contraction, mean ± SD: G1: 165 ± 158 G2: 267 ± 187 Max cystometric capacity (mL), mean ± SD: G1: 244 ± 168 G2: 342 ± 167 | Incontinence episodes/day, mean ± SD: G1: 2.4 ± 2.4 G2: 2.6 ± 3.3 G1/BL: P < 0.001 G2/BL: P < 0.001 G1/G2: P = NS Patient assessment of efficacy, VAS score, mean change ± SD: G1: 5.8 ± 4.2 G2: 6.0 ± 3.3 G1/BL: P < 0.001 G2/BL: P < 0.001 G1/G2: P = 0.9 Bladder volume (mL), first contraction, mean ± SD: G1: 229 ± 189 G2: 302 ± 198 G1/BL: P = 0.0055 G2/BL: P = 0.1428 G1/G2: P = 0.57 Max cystometric capacity (mL), mean ± SD: G1: 297 ± 176 G2: 387 ± 162 G1/BL: P = 0.0011 G2/BL: P = 0.0538 G1/G2: P = NR Dry mouth, n (%): G1: 15 (39) G2: 31 (82) Constipation, n (%): G1: 8 (21) G2: 19 (50) Somnolence, n (%): G1: 7 (18) G2: 14 (37) Nausea, n (%): G1: 3 (8) G2: 10 (26) Dizziness, n (%): G1: 6 (16) G2: 10 (26) Blurred vision, n (%): G1: 7 (18) G2: 9 (24) Urinary retention, n (%): G1: 9 (24) G2: 13 (34) Impaired vision, n (%): G1: 9 (24) G2: 9 (24) Palpitation, n (%): G1: 3 (8) G2: 5 (13) Dry mouth by unvalidated questionnaire, %: G1: 38 G2: 94 P < 0.001 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: − Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Diokno et al., 1995 Country and setting: US, private clinic Enrollment period: January 1992 to December 1992 Funding: NR Author industry relationship disclosures: NR | Design: Cohorts with comparison; (Series of patients self selected into two groups) Intervention: Bladder training vs. anticholinergic or antispasmodic Groups: G1: Bladder training G2: oxybutynin 2.5–5.0 mg b.i.d. or t.i.d. N at enrollment: G1: 39 G2: 33 N at follow-up: G1: 26 G2: 28 Age, mean (range): 64 (20–93) Race/ethnicity: NR Women, N (%): 72 (100) | Inclusion criteria: • Incontinent by AHCPR guidelines* • Incontinence persisted after treatment for transient incontinence Exclusion criteria: • Post-void residual of more than 150 mL | UUI, n (%): G1: 27 (49) G2: 28 (51) MUI with predominant urge, n (%): G1: 12 (71) G2: 5 (29) | Continent, n (%): G1: 1 (4) G2: 1 (4) Improved, n (%): G1: 22 (85) G2: 19 (68) No Change, n (%): G1: 3 (11) G2: 8 (28) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: − Loss to followup: − Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: poor Age: −, NR Baseline OAB status: NR Baseline characteristics: − Length of followup: ++ Measurement methods: − Measurement reliability: − Intervention description: +
Author: Diokno et al., 2002 Country and setting: US, Community-dwelling Enrollment period: NR Funding: NR Author industry relationship disclosures: 1 of 7 ALZA Corp (1) | Design: Multicenter, open-label, prospective cohort with 12 mos follow-up Intervention: Oxybutynin chloride ER Groups: NA N at enrollment: 1,067 N at follow-up: 493 Women, n (%): 904 (84.7) Age, mean ± SD: 64 ± 14.4 Age, n (%): < 40: 65 (6.1) 40–65: 415 (38.9) >65–74: 313 (29.3) ≥ 75: 274 (25.7) Race/ethnicity, n (%): White: 950 (89.0) Black: 82 (7.7) Hispanic: 28(2.6) Asian: 2 (0.2) Native American: 5 (0.5) Follow-up: 12 months | Inclusion criteria: • Community-dwelling • Urge or mixed incontinence • Age ≥ 18 • Generally in good health Exclusion criteria: • UTI • Prostatitis • Urinary tract obstruction • Bladder tumor • Bladder stone • Prostate cancer • Contraindication to study drug • Current drug or alcohol abuse • Pregnant or breastfeeding • Pre-existing severe GI narrowing • Taken an investigational drug ≤ 1 mo • Known allergy or hypersensitivity to oxybutynin chloride • Not able to swallow medication whole | Incontinence impact, mean score ± SD: 1.4 ± 0.72 Sleep impact, mean score ± SD: 3.3 ± 1.67 Bother score, estimated from figure, mean: 72 | Incontinence impact, end of dose adjustment, mean change ± SD: −0.5 ± 0.70 P < 0.001 Incontinence impact, 90 days, mean change ± SD: −0.6 ± 0.76 P < 0.001 Incontinence impact, final measure, mean change ± SD: −0.5 ± 0.77 P < 0.001 Sleep impact, end of dose adjustment, mean change ± SD: −1.0 ± 1.73 P < 0.001 Sleep impact, 90 days, mean change ± SD: −1.2 ± 1.82 P < 0.001 Sleep impact, final measure, mean change ± SD: −1.1 ± 1.81 P < 0.001 Bother score, end of dose adjustment, estimated from figure, mean: 44 P < 0.001 Bother score, 90 days, estimated from figure, mean: 42 P < 0.001 Bother score, 12 mos, estimated from figure, mean: 39 P < 0.001 Headache, %: 1–90 days: 6.2 91–180 days: 0.6 181–270 days: 0.4 271–364 days: 0.4 Total: 7.6 Dizziness, %: 1–90 days: 5.0 91–180 days: 0.4 181–270 days: 0.2 271–364 days: 0 Total: 5.6 Blurred vision, %: 1–90 days: 2.8 91–180 days: 0.4 181–270 days: 0.1 271–364 days: 0 Total: 3.3 Somnolence, %: 1–90 days: 2.8 91–180 days: 0 181–270 days: 0.2 271–364 days: 0 Total: 3.0 Confusion, %: 1–90 days: 1.1 91–180 days: 0.1 181–270 days: 0.2 271–364 days: 0 Total: 1.4 Discontinued due to AEs, n (%): 256 (24) Discontinued due to lack of efficacy, n (%): 108 (10.1) Discontinued due to administrative reasons, n (%): 90 (8.4) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: NR Baseline characteristics: − Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Diokno et al., 2003* Chu et al., 2005† Country and setting: US, Academic medical center Enrollment period: November 2000 to October 2001 Funding: ALZA Corporation, Ortho-McNeil Pharmaceuticals Author industry relationship disclosures: 5 of 7* ALZA (1) Indevus (1) Ortho-McNeil (4) Pharmacia (1) Watson (1) NR† | Design: RCT Intervention: Oxybutynin ER vs Tolterodine ER 12 week treatment period Groups: G1: Oxybutynin ER 10 mg daily G2: Tolterodine ER 4mg daily N at enrollment: G1: 391 G2: 399 N at follow-up: G1: 339 G2: 357 Age, mean (range): G1: 60 (23–92) G2: 60 (18–85) Race/ethnicity, N (%): White: G1: 329 (84) G2: 342 (86) Black: G1: 32 (8) G2: 35 (9) Hispanic: G1: 27 (7) G2: 19 (5) Other: G1: 3 (1) G2: 3 (1) Women, N (%): G1: 391 (100) G2: 399 (100) | Inclusion criteria: • Age ≥ 18 • ≥ 21 episodes UUI/week • ≥ 10 voids/day • Urge > non-urge incontinence Exclusion criteria: • Treatable GU conditions causing incontinence • PVR > 150 mL by ultrasound x 2 • Risk of developing complete urinary retention • Medical problems worsened by anticholinergic effects • Hematuria • Uncontrolled narrow angle glaucoma • Obstructive uropathy • Reduced GI motility • Hypersensitivity to medications | UUI episodes/wk, mean ± SD: G1: 37.2 ± 15.2 G2: 36.9 ± 14.1 Total incontinence episodes/wk, mean ± SD: G1: 43.3 ± 19.3 G2: 42.6 ± 18.2 Voids/wk, mean ± SD: G1: 94.8 ± 25.4 G2: 96.2 ± 24.5 | UUI episodes/wk, mean: G1: 10.8 G2: 11.2 P = 0.28 Incontinence episodes/wk, mean: G1: 12.3 G2: 13.8 P = 0.08 Voids/wk, mean: G1: 66.4 G2: 71.1 P = 0.03 UUI episodes/wk, % reduction ± SD: G1: 72.0 ± 34.0 G2: 70.2 ± 33.2 P = 0.13 Incontinent episodes/wk, % reduction ± SD: G1: 72.8 ± 31.0 G2: 69.1 ± 34.9 P = 0.08 Voids/wk, % reduction ± SD: G1: 27.7 ± 19.7 G2: 24.9 ± 18.9 P = 0.05 Total dryness, %: G1: 23 G2: 16.8 P = 0.03 No UUI episodes, %: G1: 26.7 G2: 20.9 P = 0.06 Dry mouth, any degree, n (%): G1: 116 (29.7) G2: 89 (22.3) P = 0.02 Dry Mouth, mild, n (%): G1: 87 (22.3) G2: 69 (17.3) Dry mouth, moderate-severe, n (%): G1: 29 (7.4) G2: 20 (5.0) Constipation, n (%): G1: 25 (6.4) G2: 31 (7.8) Diarrhea, n (%): G1: 31 (7.9) G2: 25 (6.3) Headache, n (%): G1: 22 (5.6) G2: 24 (6.0) UTI, n (%): G1: 20 (5.1) G2: 13 (3.3) CNS AE, n (%):† G1: 35 (9.0) G2: 33 (8.3) Dizziness, n (%):† G1: 15 (3.8) G2: 10 (2.5) Dizziness, mild,** %:† G1: 1.8 G2: 1.5 Dizziness, moderate,** %:† G1: 0.8 G2: 0.3 Somnolence, n (%):† G1: 4 (1.0) G2: 9 (2.3) Somnolence, mild,** %:† G1: 0.5 G2: 1.5 Somnolence, moderate,** %:† G1: 0.3 G2: 0.5 Insomnia, n (%):† G1: 7 (1.8) G2: 3 (0.8) Insomnia, mild** %:† G1: 0.8 G2: 0 Insomnia, moderate,** %:† G1: 0.5 G2: 0 Depression, n (%):† G1: 5 (1.3) G2: 3 (0.8) Hypertonia, n (%):† G1: 2 (0.5) G2: 4 (1.0) Hypertonia, mild,** %:† G1: 0 G2: 0 Hypertonia, moderate,** %:† G1: 0.3 G2: 0 Anxiety, mild,** %:† G1: 0.5 G2: 0 Anxiety, moderate,** %:† G1: 0.3 G2: 0 Nervousness, mild,** %:† G1: 0 G2: 0 Nervousness, moderate,** %:† G1: 0.3 G2: 0 Tremor, mild,** %:† G1: 0.3 G2: 0.3 Tremor, moderate,** %:† G1: 0 G2: 0 Confusion, mild,** %:† G1: 0.3 G2: 0.3 Confusion, moderate,** %:† G1: 0 G2: 0 | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: − Masking: + Pt selection criteria: + Loss to followup: ++ Drop-out rates: ++ Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Dmochowski et al., 2002 Country and setting: US, Community Enrollment period: NR 2 week washout 12 week treatment period Funding: NR Author industry relationship disclosures: 7 of 7 Abbot (1) Alza (3) Amgen (1) AstraZeneca (1) Bayer (1) Bioform (1) Genyx (1) Glaxo (1) Interneuron (2) Lilly (2) Merck (1) Otsulta (1) Pharmacia (3) Pfizer (1) Praecis (2) Roche (1) Seprecor (1) Surx (1) Synthelabo (1) Vivus (1) Watson (7) Yamanouchi (1) | Design: RCT Followed by: 12 week open label dose titration Intervention: Oxybutynin TDS vs. placebo Groups: G1: OXY TDS 1.3 mg G2: OXY TDS 2.6 mg G3: OXY TDS 3.9 mg G4: placebo N at enrollment: G1: 130 G2: 133 G3: 125 G4: 132 N at follow-up: G1: 128 G2: 131 G3: 123 G4: 130 Women, N (%): G1: 120 (92.3) G2: 123 (92.5) G3: 114 (91.2) G4: 121 (91.7) Age, mean ± SD: G1: 61.5 ± 11.8 G2: 61.9 ± 13.5 G3: 59.4 ± 14.5 G4: 62.7 ± 13.1 Race/ethnicity, n (%): White: G1: 119 (91.5) G2: 118 (88.7) G3: 118 (94.4) G4: 118 (89.4) Black: G1: 7 (5.4) G2: 10 (7.5) G3: 3 (2.4) G4: 11 (8.3) Other: G1: 4 (3.1) G2: 5 (3.8) G3: 4 (3.2) G4: 3 (2.3) | Inclusion criteria: • Age ≥ 18 • History of OAB • ≥ 10 episodes UUI either pure urge or predominant urge on 7 day voiding diary • ≥ 56 voids/7 day diary •Average recorded urinary volume of ≤ 350 mL Exclusion criteria: • Incontinence related to chronic illness • Concomitant medications • History of lower urinary tract surgery in ≤ 6 mos • IC • Urethral syndrome • Painful bladder syndrome • Overflow urinary incontinence • Alcohol/drug abuse • Known hypersensitivity to oxybutynin, similar compounds or transdermal systems • Active skin disorder • Narrow angle glaucoma • Excessive caffeine intake > 5 cups/day | Incontinence episodes/week, median: G1: 31.0 G2: 30.0 G3: 31.0 G4: 30.0 Voids/day, mean ± SD: G1: 12.4 ± 2.9 G2: 12.1 ± 3.3 G3: 12.3 ± 3.3 Voided volume (mL), mean: G1: 175 G2: 165 G3: 156 G4: 170 Open Label: Incontinence episodes/week, open label, median: G1: 30.0 G2: 29.0 G3: 37.0 G4: NA Prior years incontinent, years, mean ± SD: G1: 9.1 ± 10.3 G2: 8.9 ± 8.8 G3: 9.9 ± 9.8 G4: 9.1 ± 9.1 IIQ (QoL), total score, mean: G1: 167 G2: 161 G3: 144 G4: 160 Prior anticholinergic treatment, n, (%): G1: 30 (23.1) G2: 28 (21.1) G3: 28 (22.4) G4: 27 (20.5 | Incontinence episodes/week, median change: G1: −16.0 G2: −14.0 G3: −19.0 G4: −14.5 G3/G4: P < 0.0165 Voids/day, mean change ± SD: G1: −1.8 ± 2.6 G2: −1.8 ± 2.4 G3: −2.3 ± 2.5 G4: −1.7 ± 3.0 G3/G4: P = 0.0457 Voided volume, mL, mean increase ± SD: G1: −2 G2: 19 G3: 24 G4: 6 G3/G4: P = 0.0063 G2/G4: P = 0.0157 Open Label: Incontinence episodes/week, median change: G1: −18.0 G2: −17.0 G3: −19.0 G4: NA IIQ (QoL), total score, mean change: G1: 119 G2: 104 G3: 89 G4: 113 G3/G4: P = 0.0327 UDI (QoL), total score, mean ± SD: G1: NR G2: NR G3: 78.8 ± 51.9 G4: 94.7 ± 50.0 G3/G4: P = 0.0266 Dry mouth, n (%): G1: 6 (4.6) G2: 9 (6.8) G3: 12 (9.6) G4: 11 (8.3) Dizziness, n (%): G1: 2 (1.5) G2: 4 (3.0) G3: 5 (4.0) G4: 5 (3.8) Dysuria, n (%): G1: 1 (0.8) G2: 3 (2.3) G3: 3 (2.4) G4: 0 (0) Somnolence, n (%): G1: 1 (0.8) G2: 0 (0) G3: 2 (1.6) G4: 1 (0.8) Nausea, n (%): G1: 6 (4.6) G2: 5 (3.8) G3: 2 (1.6) G4: 7 (5.3) Constipation, (%): G1: 7 (5.4) G2: 3 (2.3) G3: 1 (0.8) G4: 4 (3.0) Palpitations, n (%): G1: 1 (0.8) G2: 0 (0) G3: 1 (0.8) G4: 0 (0) Vision abnormal, n (%): G1: 3 (2.3) G2: 2 (1.5) G3: 0 (0) G4: 2 (1.5) Localized application site reactions, n (%): G1: 32 (26.4) G2: 7 (5.7) G3: 8 (6.9) Application site erythema, n (%): G1: 23 (19) G2: 29 (23.6) G3: 14 (12.0) Application site erythema, mild, double blind period, n (%): G1: 79 (31.5) G2: 29 (36.2) G3: NA Application site erythema, moderate, double blind period, n (%): G1: 46 (18.3) G2: 46 (18.1) G3: NA Application site erythema, severe, double blind period, n (%): G1: 6 (2.4) G2: 8 (3.1) G3: NA Application site erythema, mild, open label, n (%): G1: 18 (34.6) G2: 58 (38.4) G3: 87 (43.9) Application site erythema, moderate, open label, n (%): G1: 7(13.5) G2: 23 (15.2) G3: 24 (12.1) Application site erythema, severe, open label, n (%): G1: 0 (0) G2: 2 (1.3) G3: 0 (0) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Dmochowski et al., 2003 Country and setting: US, Community Enrollment period: NR 2 week washout 12 week treatment period Funding: Watson Pharma Author industry relationship disclosures: 6 of 6 Watson Pharma (6) | Design: RCT Intervention: Oxybutynin TDS vs. Tolterodine ER vs. placebo, 2 week washout plus 12 weeks treatment period; drug/placebo applied transdermally twice weekly to the abdomen and oral capsule ingested once daily Groups: G1: OXY TDS 3.9 mg/day G2: Tolterodine ER 4 mg daily G3: placebo N at enrollment: G1: 121 G2: 123 G3: 117 Total: 361 N at follow-up: G1: NR G2: NR G3: NR Total: 320 (89%) Age, mean yrs ± SD: G1: 63.1 ± 12.0 G2: 62.9 ± 13.5 G3: 64.5 ± 12.3 Race/ethnicity, n (%): White: G1: 111 (91.7) G2: 120 (97.6) G3: 110 (94.0) Black: G1: 8 (6.6) G2: 1(0.8) G3: 4 (3.4) Other: G1: 2 (1.6) G2: 2 (1.6) G3: 3 (2.6) Women, N (%): G1: 109 (90.1) G2: 117 (95.1) G3: 109 (93.2) Prior antimuscarinic treatment, Tolterodine, n, (%): G1: 57 (47) G2: 60 (49) G3: 54 (46) Prior antimuscarinic treatment, Oxybutynin, n, (%): G1:61 (51) G2: 59 (48) G3: 59 (50) Prior antimuscarinic treatment, Other, n, (%): G1: 7 (6) G2: 6 (5) G3: 6 (5) | Inclusion criteria: • ≥ 18yo men and women • Current pharmacological treatment for OAB with beneficial response • ≥4 episodes UUI episodes either pure urge or predominant urge on 3 day voiding diary • ≥ 24 voids/3 day diary • Average recorded urinary volume of ≤350 mL Exclusion criteria: • History of lower urinary tract surgery in previous 6 months • IC • Urethral syndrome • Painful bladder syndrome • Overflow urinary incontinence | Incontinence episodes/day, mean ± SD: G1: 4.7 ± 2.9 G2: 5.0 ± 2.9 G3: 5.0 ± 3.2 Incontinence episodes/day, median: G1: 4 G2: 4 G3: 4 Voids/day, mean ± SD: G1: 12.4 ± 2.9 G2: 12.1 ± 3.3 G3: 12.3 ± 3.3 Voids/day, median: G1: 12 G2: 12 G3: 12 Voided volume (mL), mean ± SD: G1: 165 ± 62 G2: 165 ± 61 G3: 175 ± 68 Voided volume, mL, median: G1: 160 G2: 150 G3: 171 Global assessment of disease, QOL, mean ± SD: G1: 65 ± 19 G2: 63 ± 20 G3: 65 ± 20 IIQ (QOL), travel domain, mean ± SD: G1: 49 ± 28 G2: 47 ± 29 G3: 43 ± 29 UDI (QOL), irritative symptoms, mean ± SD: G1: 62 ± 20 G2: 66 ± 18 G3: 63 ± 20 | Incontinence episodes/day, mean ± SD: G1: 1.9 ± 2.7 G2: 1.9 ± 3.0 G3: 2.9 ± 3.8 G1/G3: P = 0.0137 G2/G3: P = 0.0011 G1/G2: P = 0.5878 Incontinence episodes/day, mean change ± SD: G1: 2.9 ± 3.0 G2: 3.2 ± 2.8 G3: 2.1 ± 3.0 Incontinence episodes/day, median G1: 1 G2: 1 G3: 2 Incontinence episodes/day, median change G1: 3 G2: 3 G3: 2 Voids/day, mean ± SD: G1: 10.4 ± 3.2 G2: 9.9 ± 3.1 G3: 10.9 ± 3.8 G1/G3: P = 0.101 G2/G3: P = 0.0025 G1/G2: P = 0.276 Voids/day, mean change ± SD: G1: −1.9 ± 2.7 G2: −2.2 ± 2.6 G3: −1 ± 1.4 Voids/day, median: G1: 10 G2: 10 G3: 10 Voids/day, median change: G1: 2 G2: 2 G3: 1 Voided volume, (mL), mean ± SD: G1: 198 ± 84 G2: 193 ± 75 G3: 182 ± 84 G1/G3: P = 0.0010 G2/G3: P = 0.0017 G1/G2: P = 0.7690 Voided volume (mL), mean change ± SD: G1: 32 ± 55 G2: 29 ± 57 G3: 9 ± 63 Voided volume (mL), median: G1: 188 G2: 189 G3: 165 Voided volume (mL), median change: G1: 24 G2: 29 G3: 5.5 Global assessment of disease, QOL, change ± SD: G1: 30 ± 30 G2: 33 ± 28 G3: 21 ± 31 G1/G3: P = 0.0106 G2/G3: P = 0.001 G1/G2: P = 0.1861 IIQ (QOL) travel domain, change ± SD: G1: 23 ± 25 G2: 22 ± 29 G3: 11 ± 30 G1/G3: P = 0.0018 G2/G3: P = 0.0045 UDI (QOL), irritative symptoms, change ± SD: G1: 25 ± 26 G2: 28 ± 26 G3: 18 ± 24 G1/G3: P = 0.0156 G2/G3: P = 0.0010 Treatment compliance with assigned dosage regimen: 92%: Frequency decreased to a greater extent for patients with > 14 micturations per day at baseline G1: −2.9/day, P = 0.0036 (data for other groups not reported) Adverse effects: Dry mouth, %: G1: 4.1 G2: 7.3 G3: 1.7 G1/G3: P = 0.2678 G2/G3: P = 0.0379 Constipation, (%): G1: 3.3 G2: 5.7 G3: NR Mild systemic adverse effects, n (%): G1: 15 (12.4) G2: 13 (10.6) G3: 6 (5.1) Moderate systemic adverse effects, n (%) G1: 7 (5.8) G2: 13 (10.6) G3: 7 (6.0) Severe systemic adverse effects, n (%) G1: 1 (0.8) G2: 3 (2.4) G3: 1 (0.9)Mild localized application site reactions, n (%): G1: 9 (7.4) G2: 2 (1.6) G3: 5 (4.3) Moderate localized application site reactions, n (%): G1: 17 (14.0) G2: 4 (3.3) G3: 2 (1.7) Severe localized application site reactions, n (%): G1: 6 (5.0) G2: 1 (0.8) G3: 1 (0.9) Treatment discontinuation due to adverse effects, n (%): G1: 13 (10.7) (12 due to application site reactions, 1 due to hot flushes) G2: 2 (1.6) (1 due to fatigue and 1 due to dizziness) G3: NR Postvoid residual>150 mL at end of treatment: G1: 4 G2: 4 G3: 3 No reports of symptomatic urinary retention Withdraw due to AEs: 23 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Dmochowski et al., 2007 Country and setting: International, multicenter Enrollment period: NR Funding: Pfizer Inc. Author industry relationship disclosures: 5 of 5 Astellas (2) Esprit (1) Lilly (1) Merck (1) Novartis (2) Ortho-McNeil (1) Pfizer (5) Watson (1) | Design: RCT (subanalysis) Intervention: Tolterodine ER vs. placebo Groups: G1: Tolterodine ER 4mg po qAM G2: Placebo qAM N at enrollment: Total: 1015 G1: 507 G2: 508 N at follow-up: G1: 507 G2: 507 Age, yrs (range): G1: 60 (20–89) G2: 61 (22–93) Race/ethnicity, %: White: G1: 95 G2: 94 Black: G1: 3 G2: 4 Other: G1: 1 G2: 2 Women, %: 81 Follow-up: 12 wks | Inclusion criteria: • Age ≥18 • ≥ 8 voids/day and ≥ 5 episodes/wk UUI x 6 mos Exclusion criteria: • Hepatic, renal disease • UTI, recurrent UTIs • SUI • BOO • Indwelling catheter • Self catheterization • Taking anticholinergic medication • Mean voided volume > 200 mL or total daily voided volume > 3000 mL | UUI episodes/wk, mean ± SD: G1: 22.1 ± 22.3 G2: 23.3 ± 20.7 UUI episodes/wk, 24:00-06:00, mean ± SD: G1: 3.5 ± 5.0 G2: 3.9 ± 5.0 UUI episodes/wk, 06:00–12:00, mean ± SD: G1: 6.9 ± 8.1 G2: 6.7 ± 6.7 UUI episodes/wk, 12:00–18:00, mean ± SD: G1: 6.9 ± 8.2 G2: 7.2 ± 6.9 UUI episodes/wk, 18:00–24:00, mean ± SD: G1: 5.3 ± 8.1 G2: 5.5 ± 5.8 Voids/day, mean ± SD: G1: 10.9 ± 4.2 G2: 11.3 ± 3.8 Voids/day, 24:00-06:00, mean ± SD: G1: 1.7 ± 1.0 G2: 1.8 ± 1.1 Voids/day, 06:00–12:00, mean ± SD: G1: 3.3 ± 1.4 G2: 3.4 ± 1.3 Voids/day, 12:00–18:00, mean ± SD: G1: 3.1 ± 1.4 G2: 3.2 ± 1.3 Voids/day, 18:00–24:00, mean ± SD: G1: 2.8 ± 1.3 G2: 2.9 ± 1.1 Voided volume (mL), mean ± SD: G1: 141 ± 43 G2: 136 ± 42 Voided volume (mL), 24:00-06:00, mean ± SD: G1: 201± 99 G2: 190 ± 96 Voided volume (mL), 06:00–12:00, mean ± SD: G1: 141 ± 52 G2: 139 ± 55 Voided volume (mL), 12:00–18:00, mean ± SD: G1: 126 ± 49 G2: 119 ± 45 Voided volume (mL), 18:00–24:00, mean ± SD: G1: 129 ± 50 G2: 123 ± 47 | UUI episodes/wk, mean change ± SD: G1: −11.8 ± 17.8 G2: −6.9 ± 15.4 P ≤ 0.001 Benefit ratio 1.71 UUI episodes/wk, 24:00-06:00, mean change ± SD: G1: −1.6 ± 4.0 G2: −1.0 ± 3.5 P ≤ 0.001 Benefit ratio 1.53 UUI episodes/wk, 06:00–12:00, mean change ± SD: G1: −3.7 ± 7.1 G2: −2.0 ± 5.4 P ≤ 0.001 Benefit ratio 1.82 UUI episodes/wk, 12:00–18:00, mean change ± SD: G1: −3.9 ± 7.1 G2: −2.2 ± 5.7 P ≤ 0.001 Benefit ratio 1.82 UUI episodes/wk, 18:00–24:00, mean change ± SD: G1: −3.0 ± 6.9 G2: −1.6 ± 4.5 P ≤ 0.001 Benefit ratio 1.89 Voids/day, mean change ± SD: G1: −1.8 ± 3.4 G2: −1.2 ± 2.9 P ≤ 0.001 Benefit ratio 1.46 Voids/day, 24:00-06:00, mean change ± SD: G1: −0.22 ± 0.7 G2: −0.17 ± 0.8 P ≤ 0.05 Benefit ratio 1.29 Voids/day, 06:00–12:00, mean change ± SD: G1: −0.57 ± 1.2 G2: −0.35 ± 1.0 P ≤ 0.001 Benefit ratio 1.60 Voids/day, 12:00–18:00, mean change ± SD: G1: −0.55 ± 1.2 G2: −0.39 ± 1.0 P ≤ 0.001 Benefit ratio 1.42 Voids/day, 18:00–24:00, mean change ± SD: G1: −0.43 ± 1.1 G2: −0.30 ± 0.8 P ≤ 0.002 Benefit ratio 1.43 Voided volume (mL), mean change ± SD: G1: 34.1 ± 50.5 G2: 14. 0± 41.3 P ≤ 0.001 Benefit ratio 2.44 Voided volume (mL), 24:00-06:00, mean change ± SD: G1: 33.8± 105.5 G2: 16.7 ± 87.7 P ≤ 0.002 Benefit ratio 2.03 Voided volume (mL), 06:00–12:00, mean change ± SD: G1: 38.2 ± 63.9 G2: 15.5± 58.6 P ≤ 0.001 Benefit ratio 2.47 Voided volume (mL), 12:00–18:00, mean change ± SD: G1: 31.5 ± 59.4 G2: 12.4 ± 42.4 P ≤ 0.001 Benefit ratio 2.55 Voided volume (mL), 18:00–24:00, mean change ± SD: G1: 29.2 ± 55.0 G2: 12.0 ± 49.6 P ≤ 0.001 Benefit ratio 2.44 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: − Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Dmochowski et al., 2008 Country and setting: US, 62 sites Enrollment period: September 2005 to June 2006 Funding: Esprit Pharma and Indevus Pharmaceuticals Inc. Author industry relationship disclosures: 4 of 4 Allergan (4) Astellas (3) Eli Lilly (1) Esprit Pharma (4) GSK (2) Indevus (4) Medtronics (1) Novartis (3) Ortho (2) Pfizer (2) Schwarz Pharma (1) Watson (4) | Design: RCT Intervention: Trospium vs. placebo Groups: G1: Trospium 60 mg qd G2: Placebo N at enrollment: G1: 280 G2: 284 N at follow-up: G1: 267 G2: 276 Women, n (%): G1: 230 (82.1) G2: 249 (87.7) Age, mean (SE): G1: 61.2 (0.7) G2: 58.4 (0.7) Race/ethnicity, n (%): White: G1: 245 (87.5) G2: 234 (82.4) Black: G1: 18 (16.4) G2: 28 (9.9) Hispanic: G1: 12 (4.3) G2: 14 (4.9) Asian: G1: 2 (0.7) G2: 3 (1.1) Other: G1: 3 (1.1) G2: 5 (1.8) | Inclusion criteria: • Age ≥ 18 • Symptoms of OAB ≥ 6 mos duration • Urinary frequency (mean of ≥ 10 toilet voids per day) • Urgency (1 or more episodes of severe urgency associated with a toilet void) • UUI (a mean of 1 or more UUI episodes per day) Exclusion criteria: • Total voided volumes > 3000 mL/day • Mean voided volume > 250 mL • Predominantly SUI • Insensate, or overflow incontinence • Neurogenic bladder • Indwelling or intermittent catheterization • Renal disease (serum creatinine >1.5 mg/dL) • Uninvestigated hematuria • UTI • History of > 3 UTIs in the previous 12 mos • Urinary retention (PVR > 100 mL) • Cancer • Interstitial cystitis • PSA > greater than 4 ng/mL • Prostate cancer, or chronic prostatitis | UUI episodes/day, mean (SE): G1: 4.0 (0.2) G2: 4.0 (0.2) Urgency severity, mean (SE): G1: 1.82 (0.03) G2: 1.83 (0.03) Voids/day, mean (SE): G1:12.8 (0.2) G2: 12.9 (0.2) Prior anticholinergic use for OAB, mean (SE): G1: 142 (50.7) G2: 156 (54.9) Voided volume (mL), mean (SE): G1: 149.1 (2.9) G2: 151.8 (2.8) | UUI episodes/day, 12 wks, mean change (SE): G1: −2.4 (0.2) G2: −1.6 (0.2) G1/BL: P ≤ 0.001 Urgency severity, 12 wks, mean change (SE): G1: −0.28 (0.03) G2: −0.13 (0.03) G1/BL: P ≤ 0.001 Voids/day, 12 wks, mean change (SE): G1: −2.5 (0.2) G2: −1.8 (0.2) G1/BL: P ≤ 0.001 Voided volume (mL), 12 wks, mean change (SE): G1: 31.5 (3.4) G2: 17.8 (3.3) G1/BL: P ≤ 0.01 Treatment emergent AE, n (%): G1: 154 (55) G2: 130 (45.8) Mild to Moderate AEs, %: G1: 87% G2: 91.5% Dry mouth, n (%): G1: 36 (12.9) G2: 12 (4.6) Constipation, n (%): G1: 21 (7.5) G2: 5 (1.8) Headache, n (%): G1: 5 (1.8) G2: 6 (2.1) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: + Pt selection criteria: + Loss to followup: ++ Drop-out rates: + Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Drutz et al., 1999 Country and setting: 25 centers United States and Canada Enrollment period: NR Funding: Pharmacia & Upjohn AB, Uppsala, Sweden Author industry relationship disclosures: NR | Design: RCT Intervention: Tolterodine vs. oxybutynin vs. placebo Groups: 2 wk washout/run-in period G1: Tolterodine 2 mg b.i.d. × 12 wks G2: Oxybutynin 5 mg t.i.d. × 12 wks G3: placebo N at enrollment: G1: 109 G2: 112 G3: 56 N at follow-up: Protocol correct G1: 70 G2: 41 G3: 36 Age, mean range: G1: 63.0 (31–88) G2: 66.3 (23–91) G3: 62.1 (26–87) Women, %: G1: 81 G2: 91 G3: 80 Race/ethnicity, %: Caucasian: G1: 87 G2: 94 G3: 93 BMI, mean kg/m^2^ (range): G1: 29.0 (18.3–56.2) G2: 28.0 (16.0–51.4) G3: 29.1 (17.2–52.8) | Inclusion criteria: • Age≥18 yrs • Provided written informed consent • Post-menopausal • Surgically sterile • Adequate contraception • Detrusor overactivity on subtracted cystometry • Urinary frequency (58 voids on average per 24 hrs) and either urge incontinence (51 incontinence episode on average per 24 hrs Exclusion criteria: • SUI • Hepatic or renal disease • Recurrent UTIs • Interstitial cystitis • Hematuria or hematuria secondary to malignant disease • Indwelling catheter or intermittent catheterization • Treatment with investigational drug in ≤ 2 mos • Treatment with tolterodine or electro-stimulation therapy or BT ≤ 14 days • Treatment with anticholinergic drug, or any drug for urinary urge • Incontinence ≤ 14 days • Unstable dosage of any anticholinergic • Serious adverse effects on oxybutynin • Average total voided volume/24 hours of >3000 mL • Clinically significant voiding difficulty with risk of urinary retention (such as residual volume >200 mL or urine flow rate <10 mL/s) | Duration of symptoms >5 years (%): G1: 47 (43) G2: 41 (37) G3: 25 (45) Instability hyperreflexia (%): G1: 101:8 (93:7) G2: 100:8 (89:7) G3: 53:3 (95:5) Urgency (%): G1: 104 (95) G2: 111 (99) G3: 55 (98) Previous drug therapy for urge incontinence, (%): G1: 49 (45) G2: 50 (45) G3: 31 (55) Good response to previous drug therapy, n (%): G1: 20 (41) G2: 20 (40) G3: 12 (39) Previous surgery affecting the lower urinary tract (%): G1: 29 (27) G2: 50 (45)* G3: 19 (34) Patients with incontinence episodes, n (%): G1: 90 (83) G2: 103 (92) G3: 50 (89) Incontinence episodes/day, mean (range): G1: 3.7 (0.1–19.9) G2: 3.4 (0.1–13.4) G3: 3.5 (0.1–14.9) Patients with ≥ 8 voids/day, n (%): G1: 108 (99) G2: 110 (98) G3: 55 (98) Voids/day, mean (range): G1: 11.6 (7.7–22.0) G2: 11.5 (7.1–31.4) G3: 11.6 (6.6–21.9) Volume voided/void, mean mL (range): G1: 155 (48–290) G2: 149 (42–315) G3: 160 (33–371) *P <0.05 vs. placebo and tolterdine treatment groups. | Incontinence episodes/day, mean change ± SD: G1: −1.7 ± 2.0 G2: −1.7 ± 1.7 G3: −1.0 ± 2.2 G1/G3: P = 0.063 Mean difference (SEM): G1/G2: 0.0 (0.4) (95% CI) G1/G2: −0.7 to 0.7 Voids/day, mean change ± SD: G1: −2.0 ± (2.5) G2: −2.0 ± (2.3) G3: −1.1 ± (2.9) G1/G3: P = 0.036 Mean difference (SEM): G1/G2: 0.0 (0.4) (95% CI) G1/G2: −0.8 to 0.8 Voided volume (mL), mean change ± SD: G1: 34 ± 41 G2: 50 ± 43 G3: 12 ± 41 G1/G3: P = 0.0075 Mean difference (SEM): G1/G2: NA (95% CI) G1/G2: NA | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: + Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Dwyer et al., 2008 Country and setting: Multinational, multicenter (academic and private) Enrollment period: NR Funding: Novartis Pharma AG Author industry relationship disclosures: 6 of 7 Allergan (1) Amgen (1) AMS (1) Astellas (1) Bayer (1) GSK (1) Hospira Australia (1) Novartis (5) Ocean Spray (1) Ono (1) Pfizer (2) Spectrum (1) Sunumoto (1) | Design: Multicenter open label extension Intervention: Darifenacin 7.5 mg or 15 mg (all pts received 7.5 mg dose for 2 weeks followed by individual dose adjustments) Groups: G1: Darifenacin continuation group 7.5 or 15 mg daily N at enrollment: G1: 303 N at follow-up: G1: 300 Women, N (%): G1: 262 (86.5) Age, mean (range): G1: 57.1 (22–89) Race/ethnicity: NR Follow-up: 12 weeks followed by 2 year extension | Inclusion criteria: • Successful completion of one of 2 previous, 12-wk feeder studies with no major protocol violation • “wet OAB” (urgency, frequency, and incontinence) x 6 months • Adequate contraception if of childbearing potential • Able to complete patient diaries independently • Capable of independent toileting Exclusion criteria: • Certain concomitant medications (see previous studies) • Max darifenacin dose of 7.5 mg qd for patients taking potent inhibitors of CYP450 3A4 and pts w/moderate hepatic impairment (Child Pugh B) • Other active management strategies of OAB (bladder training) | Incontinence episodes/week, mean ± SD: G1: 20.8 ± 13.6 Incontinence episodes/week, median: G1: 17.0 KHQ incontinence impact score, mean: G1: 78.56 KHQ severity score, mean: G1: 52.56 KHQ role limitations score, mean: G1: 62.72 KHQ physical limitations score, mean: G1: 62.67 KHQ social limitations score, mean: G1: 34.28 KHQ emotions score, mean: G1: 43.85 KHQ sleep/energy score, mean: G1: 52.50 KHQ personal relationship score, mean: G1: 26.94 KHQ general health score, mean: G1: 27.25 | Incontinence episodes/week, median % change: G1: −83.3 P < 0.001 KHQ incontinence impact score, mean change: G1: −25.25 P < 0.001 KHQ severity score, mean change: G1: −13.53 P < 0.001 KHQ role limitations score, mean change: G1: −26.77 P < 0.001 KHQ physical limitations score, mean change: G1: −26.35 P < 0.001 KHQ social limitations score, mean change: G1: −15.51 P < 0.001 KHQ emotions score, mean change: G1: −12.79 P < 0.001 KHQ sleep/energy score, mean change: G1: −11.59 P < 0.002 KHQ personal relationship score, mean change: G1: −8.68 P < 0.001 KHQ general health score, mean change: G1: 2.05 P = NS | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Method and blinding: − Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Elinoff et al., 2006^ Roberts et al., 2006 Country and setting: US, 82 Primary care & Ob-Gyn offices Enrollment period: NR Funding: Pfizer Author industry relationship disclosures: 6 of 6 Pfizer (6) Astellas (1) Novartis (1) | Design: Open-label, single-arm cohort Intervention: Tolterodine ER 4 mg qd for 12 wks Groups: NA N at enrollment: 896 N at follow-up: 758 Age, yrs ± SD: 56 ± 15 Race/ethnicity, n (%): White: 691 (80) Black: 94 (11) Asian: 22 (3) Other: 53 (6) Women, N (%): 708 (82) Parity: NR | Inclusion criteria: • Age ≥ 18 • OAB symptoms for ≥3 mos • ≥ 8 voids/day • 2+ episodes of urgency or UUI in a 3-d period • 3+ on the OAB Bother Rating Scale Exclusion criteria: • Stress, functional, or overflow incontinence • Acute UTI • Clinically significant LUT pathology • Indwelling catheter • Intermittent self-catherization • Use of anticholinergics, antimuscarinics for OAB, drugs to treat UUI, potent cytochrome P450 3A4 inhibitors, or investigational drugs | Duration of OAB (yrs), mean ± SD: 6 ± 8 Duration on study drug (days), mean ± SD: 80 ± 19 Daytime voids/day, mean ± SD: 9.3 ± 2.8 Nocturia episodes/day, mean ± SD: 3.0 ± 1.7 UUI episodes/day, mean ± SD: 2.7 ± 3.2 Urgency episodes/day, mean ± SD: 5.0 ± 3.8 OAB-q scores: Symptom bother: 60.0 Coping: 50.0 Concern: 51.4 Sleep: 44.4 Social Interaction: 84.0 Total HRQL: 55.2 AUA-SI: Total: 18 Irritative: 10 Obstructive: 8 Most bothersome symptom, n (%) Daytime frequency: 256 (30) Nocturnal frequency: 241 (28) UUI: 206 (24) Urgency: 154 (18) | UUI episodes/day, week 12, mean % change (95% CI):^ −86.1 (−91.7, −80.0)* UUI episodes/day, week 12, UUI most bothersome, mean % change (95% CI):^ −80.0 (−85.7, −69.2)* Urgency episodes/day, week 12, mean % change (95% CI):^ −75.0 (−80.0, −71.4)* Urgency episodes/day, week 12, urgency most bothersome, mean % change (95% CI):^ −78.4 (−83.3, −72.2)* Nocturia episodes/day, week 12, mean % change (95% CI):^ −37.5 (−40.0, −33.3)* Nocturia episodes/day, week 12, nocturia most bothersome, mean % change (95% CI):^ −40.0 (−42.9, −33.3)* Daytime voids/day, week 12, mean % change (95% CI):^ −29.0 (−31.0, −27.3)* Daytime voids/day, week 12, daytime voids most bothersome, mean % change (95% CI):^ −30.4 (−33.3, −27.3)* OAB-q scores, 12 weeks, median change (95% CI):* Symptom bother: −37.5 (−37.5, −35.0) Coping: 32.5 (30.0, 35.0) Concern: 34.3 (31.4, 37.1) Sleep: 28.0 (28.0, 32.0) Social Interaction: 12.0 (12.0, 16.0) Total HRQL: 28.9 (27.2, 31.2) AUA-SI, Median change from baseline to 12 wks (95% CI):* Total: −9 (−9, −8) Irritative: −5 (−5, −5) Obstructive: −4 (−4, −3) *P < 0.0001 vs. baseline All-cause AE, %: 51 Discontinued treatment, n %: 15 (7) Trt-related AE, %: 23 Dry mouth, %: 10.0 Constipation, %: 3.7 Headache, %: 3.0 UTI, %: 2.7 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: + Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Fantl et al., 1981 Country and setting: US, University Enrollment period: N/A Funding: NR Author industry relationship disclosures: NR | Design: Retrospective chart review Intervention: Bladder retraining drill (BRD) and anticholinergics when BRD not satisfactory Groups: G1: Detrusor muscle contraction approximately 5 seconds after a cough G2: Detrusor muscle contracts spontaneously without prior provocation G3: Both cough contraction and spontaneous contraction N at enrollment: G1: 39 G2: 4 G3: 49 N at follow-up: NA Women, %: 100 Age, mean ± SD: 42.7 ± 10:3 Race/ethnicity: NR Parity, mean: 3.5 | Inclusion criteria: • Cystometric tracings showed a rise of 15 cm water or more in intravesical pressure when recorded independently and calculated by subtraction from intra-abdominal transrectal pressures Exclusion criteria: • Neuropathic conditions • UTI | Urgency and frequency, n (%): 72 (78.2) Urinary incontinence, n (%): 65 (70.6) Sensation of incomplete voiding, n (%) 59 (64.1) Nocturia, n (%): 66 (71.7) Dysuria, n (%): 3 (3.2) MUI, n (%): 6 (6.5) Enuresis in childhood, n (%): 5 (5.4) Previously operated on for similar urologic symptoms, n (%): 34 (36.9) | Cured, n (%): G1: 32 (82.1) G2: 1 (25) G3: 41 (83.7) Cured by BRD alone, n (%): 44 (78.6) Cured by BRD + anticholinergics, n (%):* 30 (83.5) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: NR Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: NA Measurement methods: + Measurement reliability: − Intervention description: −
Author: Garely et al., 2006 Country and setting: US, 207 centers Enrollment period: June 2004 to April 2005 Funding: Astellas Pharma US, Inc. and GlaxoSmithKline Author industry relationship disclosures: 2 of 5 Astellas (2) | Design: Phase IIIb trial Intervention: Treatment with 5 mg solifenacin succinate. Dosage could be increased to 10 mg, maintained or decreased in response to pt perceived efficacy and tolerability N at enrollment: 2,205 N at follow-up: 1,743 Women, N (%): 1813 (82.2) Age, mean ± SD: 59.7 ± 14.4 Race/ethnicity, n (%): White: 1,761 (79.9) Black: 274 (12.4) Other: 170 (7.7) Weight, mean ± SD: 182.2 ± 47.0 Follow-up: 12 weeks | Inclusion criteria: • ≥ 18 yrs •OAB symptoms ≥ 3 months • Toilet without difficulty • Other OAB meds with washout period ≥ 7 days • Non-drug treatment of OAB if established ≥ 4 wks prior to study and continued Exclusion criteria: • SUI • Stress predominant MUI • UTI or chronic inflammation • Outflow obstruction due to benign prostatic hyperplasia • Uncontrolled narrow-angle glaucoma • Urinary or gastric retention • Severe renal or hepatic impairment • Chronic severe constipation or diagnosed gastrointestinal obstructive disease • Bladder cancer • Pregnant or not using reliable method of birth control • Known hypersensitivity to study medication, its components, or to anticholinergic medication | UUI, physician assessment, n (%): 1,586 (71.9) Urgency, physician assessment, n (%): 2,007 (91.0) Frequency, physician assessment, n (%): 1,969 (89.3) Nocturia, physician assessment, n (%): 1,792 (81.3) Perception of bladder condition, mean: 4.4 Most bother-some OAB symptom, n (%): Frequency: 619 (28.1) UUI: 602 (27.3) Urgency: 508 (23.0) Nocturia: 337 (15.3) None: 139 (6.3) Duration of OAB, n (%): 3 mo to 1 year: 349 (15.8) > 1 to 5 years: 1,124 (51.0) > 5 years: 732 (33.2) | Flexible drug admin dose, wk 4, n (%): Remained at 5 mg/d: 941 (45.3) 5 mg/d to 10 mg/d: 1,076 (51.8) Discontinued: 60 (2.9) Flexible drug admin dose, wk 8, n (%): Remained at 5 mg/d: 782 (43.3) 5 mg/d to 10 mg/d: 166 (17.6) Remained at 10 mg/d: 1,018 (56.4) 10 mg/d to 5 mg/d: 491 (8.5) Discontinued: 4 (0.2) Perception of bladder condition, wk 4, mean: 3.3 P < 0.001 Perception of bladder condition, wk 12 early termination, mean: 2.9 P < 0.001 Perception of bladder condition, endpoint, mean: 2.9 P < 0.001 Urgency bother, VAS score (mm), mean (n): 29.1 (1,781) UUI bother, VAS score (mm), mean (n): 24.0 (1,504) Frequency bother, VAS score (mm), mean (n): 28.3 (1,751) Nocturia bother, VAS score mean mm (n): 28.3 (1,659) OAB-q symptom severity subscale, mean change (95% CI): −29.6 (−30.7, −28.6) P < 0.001 OAB-q coping subscale, mean change (95% CI): 27.4 (26.2, 28.5) P < 0.001 OAB-q concern subscale, mean change (95% CI): 29.6 (28.4, 30.8) P < 0.001 OAB-q sleep subscale, mean change (95% CI): 27.3 (26.1, 28.5) P < 0.001 OAB-q social interaction subscale, mean change (95% CI): 14.7 (13.7, 15.6) P < 0.001 OAB-q overall health-related QoL subscale, mean change (95% CI): 25.4 (24.4, 26.4) P < 0.001 Adverse events, n (%): 1,321 (59.4) Any treatment-related AE, n (%): 928 (41.7) Dry mouth, n (%): Mild: 352 (15.8) Moderate: 100 (4.5) Severe: 25 (1.1) Constipation, n (%): Mild: 190 (8.5) Moderate: 85 (3.8) Severe: 20 (0.9) Headache, n (%): 76 (3.4) Blurred vision, n (%): Mild: 41 (1.8) Moderate: 15 (0.7) Severe: 1 (0) Dry eye, n (%): 29 (1.3) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Garely et al., 2007* Mallett et al., 2007^ Country and setting: US, multicenter (207 sites) Enrollment period: NR Funding: Astellas Pharma US Glaxo-SmithKline Author industry relationship disclosures: 4 of 4* Astellas (4) Pfizer (1) Novartis (1) 4 of 4^ Astellas (3) GlaxoSmthKline (2) Novartis (1) Watson (1) Yamanouchi (1) | Design: Prospective case series Intervention: Flexibly dosed, once daily solifenacin (started on 5 mg/d; option of increasing to 10 mg/d at week 4; option to maintain 10 mg dose or decrease to 5 mg at wk 8); for 12 weeks of treatment 10 mg dose, %: 4 wks: G1: 55 8 wks: G1: 59 (8% went back to 5mg; 19% increased to 10 mg) Groups: G1: Urge incontinence as most bothersome symptom G2: Black participants G3: Full study population N at enrollment: G1:582 G2: 274 G3: 2205 Age, mean yrs ± SD: G1: 60.9 ± 13.1 G2: 54.7 ± 13.6 G3: 59.7 ± 14.4 Race/ethnicity, n (%): White: G1: 493 (84.7) G3: 1761 (79.9) African American: G1: 62 (10.7) G3: 274 (12.4) Other: G1: 27 (4.6) G3: 170 (7.7) Women, n (%): G1: 536 (92.1) G2: 213 (77.7) G3: 1813 (82.2) Weight (lbs), mean ± SD (range): G2: 198 ± 51.6 (100–400) G3: 182.2 ± 47.0 (80–413) | Inclusion criteria: • Age ≥ 18 • Symptoms of OAB for ≥ 3 mos • Ambulatory • Able to use the toilet without difficulty • Urgency, UUI, frequency or nocturia ≥ 3 mos Exclusion criteria: Previous use of solifenacin | UUI, n (%): G1: 582 (100%) G2: NR G3: 1596 (71.9%) Urgency, n (%): G1: 534 (91.8) G2: NR G3: 2007 (91.0) Frequency, n (%): G1: 488 (83.8) G2: NR G3: 1969 (89.3) Nocturia, n (%): G1: 438 (75.3) G2: NR G3: 1792 (81.3) Most bothersome OAB symptom Urgency, n (%): G2: 48 (17.5) G3: 508 (23.0) UUI, n (%): G1: 582 (100) G2: 63 (23.0) G3: 602 (27.3) Frequency, n (%): G2: 106 (38.7) G3: 619 (28.1) Nocturia, n (%): G2: 34 (12.4) G3: 337 (15.3) None specified, n (%): G2: 23 (8.4) G3: 139 (6.3) OAB for 3 mos -1 yr, n (%): G1: 57 (9.8) G3: 349 (15.8%) OAB for 1–5 yrs, n (%): G1: 294 (50.5) G3: 1124 (51.0) OAB for >5 yrs: G1: 231 (39.7) G3: 732 (33.2) Perception of bladder condition scale (mean): G1: 4.6 G2: 4.2 G3: 4.4 Symptom severity, mean VAS: Urinary urgency: G1: 72.3 G2: 70.8 G3: 68.7 UUI: G1: 78.5 G2: 70.8 G3: 64.1 Frequency: G1: 65.7 G2: 70.8 G3: 70.6 Nocturia: G1: 57.9 G2: 66.5 G3: 65.2 OABq, symptom severity, mean (SE): G1: 63.1 (0.84) G2: 59.4 (NR) G3: 56.9 (NR) OABq, coping, mean (SE): G1: 48.9 (1.18) G2: 46.5 (NR) G3: 53.1 (NR) OABq, concern, mean (SE): G1: 43.1 (1.12) G2: 46.6 (NR) G3: 50.8 (NR) OABq, sleep, mean (SE): G1: 55.2 (1.22) G2: 43.8 (NR) G3: 49.2 (NR) OABq, social, mean (SE): G1: 73.6 (1.14) G2: 68.9 (NR) G3: 76.0 (NR) OABq, HRQoL, mean (SE): G1: 53.4 (1.01) G2: 50.5 (NR) G3: 56.3 (NR) | Patient perception of bladder condition scale, 4 wks, mean: G1: 3.3* G2: 3.1* G3: 3.3* Patient Perception of Bladder Condition Scale, 8 wks, mean: G1: 3.0* G2: 2.7* G3: 2.9* Patient Perception of Bladder Condition Scale, 12 wks or early termination, mean: G1: 2.9* G2: 2.6* G3: 2.9* Symptom severity, mean VAS, wk 4: Urinary urgency: G1: 40.9 G2: 39.7 G3: 40.6 UUI: G1: 36.9 G2: 29.9 G3: 32.8 Frequency: G1: 34.5 G2: 39.3 G3: 39.9 Nocturia: G1: 30.4 G2: 35.4 G3: 38.2 Symptom severity, mean VAS, wk 8: Urinary urgency: G1: 31.1 G2: 29.4 G3: 30.0 UUI: G1: 28.9 G2: 22.1 G3: 24.5 Frequency: G1: 24.9 G2: 27.0 G3: 28.6 Nocturia: G1: 25.4 G2: 36.4 G3: 29.0 Symptom severity, mean VAS, wk 12 (or early termination): Urinary urgency: G1: 27.5 G2: 25.3 G3: 28.0 UUI: G1: 24.3 G2: 20.0 G3: 22.7 Frequency: G1: 21.6 G2: 24.5 G3: 27.4 Nocturia: G1: 22.0 G2: 21.4 G3: 27.2 Symptom severity, VAS, mean change from baseline (95% CI) pvalue: Urinary urgency*: G1: −43.1 (−45.8, −40.4) p < 0.001 G2: −43.0 (−47.6, −38.5) G3: −39.5 (−41.0, −38.1) p < 0.001 UUI*: G1: −51.7 (−54.5, −49.0) p < 0.001 G2: −42.3 (−47.8, −36.8) G3: −40.1 (−41.8, −38.4) p < 0.001 Frequency*: G1: −42.0 (−45.0, −39.0) p < 0.001 G2: −44.2 (−48.8, −39.6) G3: −41.8 (−43.3, −40.3) p < 0.001 Nocturia*: G1: −34.4 (−37.3, −31.5) p < 0.001 G2: −42.6 (−47.5, −37.8) G3: −36.9 (−38.4, −35.4) p < 0.001 OABq, symptom severity, mean change ( [underlined: +] SE or 95% CI)*: G1: −35.9 ± 1.08 G2: −33.6 (−37.0, −30.3) G3: −29.6 (−30.7, −28.6) OABq, coping, mean change ( [underlined: +] SE or 95% CI)*: G1: 32.5 ± 1.16 G2: 32.9 (29.3, 36.6) G3: 27.4 (26.2, 28.5) OABq, concern, mean change ( [underlined: +] SE or 95% CI)*: G1: 37.0 ± 1.21 G2: 34.0 (30.4, 37.6) G3: 29.6 (28.4, 30.8) OABq, sleep, mean change ( [underlined: +] SE or 95% CI)*: G1: 26.0 ± 1.19 G2: 33.8 (29.7, 37.9) G3: 27.3 (26.1, 28.5) UUI*: G1: −51.7 (−54.5, −49.0) p < 0.001 G2: −42.3 (−47.8, −36.8) G3: −40.1 (−41.8, −38.4) p < 0.001 Frequency*: G1: −42.0 (−45.0, −39.0) p < 0.001 G2: −44.2 (−48.8, −39.6) G3: −41.8 (−43.3, −40.3) p < 0.001 Nocturia*: G1: −34.4 (−37.3, −31.5) p < 0.001 G2: −42.6 (−47.5, −37.8) G3: −36.9 (−38.4, −35.4) p < 0.001 OABq, symptom severity, mean change ( [underlined: +] SE or 95% CI)*: G1: −35.9 ± 1.08 G2: −33.6 (−37.0, −30.3) G3: −29.6 (−30.7, −28.6) OABq, coping, mean change ( [underlined: +] SE or 95% CI)*: G1: 32.5 ± 1.16 G2: 32.9 (29.3, 36.6) G3: 27.4 (26.2, 28.5) OABq, concern, mean change ( [underlined: +] SE or 95% CI)*: G1: 37.0 ± 1.21 G2: 34.0 (30.4, 37.6) G3: 29.6 (28.4, 30.8) OABq, sleep, mean change ( [underlined: +] SE or 95% CI)*: G1: 26.0 ± 1.19 G2: 33.8 (29.7, 37.9) G3: 27.3 (26.1, 28.5) OABq, social, mean change ( [underlined: +] SE or 95% CI)*: G1: 17.7 ± 1.03 G2: 20.1 (16.7, 23.5) G3: 14.7 (13.7, 15.6) OABq, HRQoL, mean change ( [underlined: +] SE or 95% CI)*: G1: 29.6 ± 1.02 G2: 30.8 (27.5, 34.1) G3: 25.4 (24.4, 26.4) Side effects, n (%): G1: 357 (61.3) G2: 128 (46.4) G3: 1321 (59.4) Dry mouth, n (%): G1: 104 (17.9) G2: 36 (13.0) G3: 477 (21.4) Constipation, n (%): G1: 85 (14.6) G2: 19 (6.9) G3: 295 (13.3) Nausea, n (%): G1: NR G2: 7 (2.5) G3: 39 (1.8) Headache, n (%): G1: 21 (3.6) G2: 9 (3.3) G3: 76 (3.4) Blurred vision, n (%): G1: 20 (3.4) G2: 7 (2.5) G3: 57 (2.6) Upper respiratory tract infection, n (%): G1: 27 (4.6) G2: 7 (2.5) G3: 69 (3.10) UTI, n (%) G1: 21 (3.6%) G2: NR G3: NR Rash, n (%): G1: NR G2: 6 (2.2) G3: 22 (0.99) Nasopharyngitis, n (%) G1: 13 (2.2%) G2: NR G3: NR Cough, n (%) G1: 12 (2.1%) G2: NR G3: NR Withdrew, n (%): G1: NR G2: 21 (7.6) G3: 216 (9.7) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: − Loss to followup: NR Drop-out rates: + Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Ghei et al., 2006 Country and setting: UK, Primary care Enrollment period: NR Duration 16 weeks Funding: NR Author industry relationship disclosures: NR | Design: Observational cohort Intervention: Bladder retraining vs. Bladder retraining + antimuscarinic (oxybutynin IR/ER, tolterodine IR/ER, or imipramine combined with either oxybutynin or tolterodine as combination therapy) Groups: G1: Bladder retraining alone G2: Antimus-carinic therapy+ bladder retraining N at enrollment: G1: 52 G2: 656 N at Follow-up: G1: 46 G2: 501 Women, n (%): G1: 45 (86) G2: 618 (94) Age, mean ± SD: G1: 52 ± 14 G2: 54 ± 23 Race/ethnicity: NR | Inclusion criteria: • Frequency • Urgency with or without UUI Exclusion criteria: • SUI • Symptoms of BOO | Incontinence episodes/day, mean ± SD: G1: 0.47 ± 1.2 G2: 1.12 ± 1.7 P < 0.001 Voids/day, mean ± SD: G1: 14 ± 6 G2: 11 ± 6 P = 0.001 | Incontinence episodes/day, mean change difference (95% CI): G2/G1: −0.60 (−0.93, −0.27) P = 0.024 Voids/day, mean change difference (95% CI): G2/G1: 2.35 (1.4, 3.3) P < 0.001 Nocturia episodes/day, mean change difference (95% CI): G2/G1: 0.57 (0.15, 0.99) Attendance visits, n (%) Failed follow-up: G1: 6 (12) G2: 155 (23) 1 follow-up visit: G1: 10 (19) G2: 15 (2) 2 follow-up visits: G1: 18 (35) G2: 86 (13) 3 follow-up visits: G1: 9 (17) G2: 225 (35) 4 follow-up visits: G1: 9 (17) G2: 175 (27) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: − Drop-out rates: NR Power calculation: − Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: + Length of followup: + Measurement methods: + Measurement reliability: − Intervention description: +
Author: Giannitsas et al., 2004 Country and setting: Greece, Specialty treatment center Enrollment period: NR Funding: NR Author industry relationship disclosures: NR | Design: Randomized for which drug to receive first two-way crossover, table of random numbers Intervention: Oxybutynin 15 mg t.i.d. vs. Tolterodine 4mg b.i.d.; 6 weeks treatment with 3–4 weeks washout Groups: G1: Oxybutynin 15 mg t.i.d. G2: Tolterodine 4mg b.i.d. Stratified by UDS findings: a: high volume (> 250mL); low pressure (< 25cmH_2_O) b: high volume (≥ 250mL); high pressure (> 25cmH_2_O) C: low volume (< 250mL); low pressure (< 25cmH_2_O) d: low volume (< 250mL); high pressure (> 25cmH_2_O) N at enrollment:<br>Total: 128 N at follow-up: Total: 107 Ga: 6 Gb: 25 Gc: 36 Gd: 40 Women, %: 100 Age, mean ± SD: Total: 56 ±16.3 Ga: 53 ± 17.2 Gb: 57 ± 16.2 Gc: 57 ± 16.3 Gd: 54 ± 16.6 Weight (kg), mean ± SD: Total: 63 ± 5.6 Ga: 63 ± 5.6 Gb: 70 ± 9.1 Gc: 67 ± 8.8 Gd: 69 ± 7.5 | Inclusion criteria: • Age ≥ 18 • DO on urodynamics Exclusion criteria: • Symptomatic or recurrent UTI • BOO • Neurologic disease • History of previous pelvic surgery • Narrow angle glaucoma • SUI • History of anticholinergic side effects • Interstitial cystitis • Child-bearing age without BC | Voids/day, mean ± SD: Total: 8.5 ± 2.63 Ga: 7.2 ± NR Gb: 8.0 ± 2.40 Gc: 8.3 ± 2.31 Gd: 9.3 ± 2.91 Volume (mL)/day, mean ± SD: Total: 1568.5 ± 398.64 Ga: 1756 ± NR Gb: 1594.6 ± 326.12 Gc: 1678.8 ± 402.15 Gd: 1420.5 ± 384.96 Voided volume (mL), mean ± SD: Total: 196.1 ± 60.19 Ga: 253 ± NR Gb: 213.5 ± 53.57 Gc: 209.8 ± 57.43 Gd: 163.4 ± 51.97 Bladder volume (mL), first desire void, mean ± SD: Total: 105.6 ± 39.38 Ga: 109 ± NR Gb: 128.0 ± 41.78 Gc: 94.3± 35.40 Gd: 101.1 ± 38.14 Bladder volume (mL), first contraction, mean ± SD: Total: 172 ± 98.4 Ga: 258 ± NR Gb: 303.3 ± 60.51 Gc: 111.9 ± 48.11 Gd: 124.4 ± 56.66 Pressure (cmH_2_0), first contraction, mean ± SD: Total: 34.8 ± 21.97 Ga: 17.4 ± NR Gb: 37.7 ± 14.03 Gc: 18.5 ± 4.60 Gd: 50.3 ± 25.14 Overactivity index, mean ± SD: Total: 36.8 ± 31.36 Ga: 15.3 ± NR Gb: 24.8 ± 19.66 Gc: 26.3 ± 16.14 Gd: 57.0 ± 38.85 Cystometric capacity (mL), mean ± SD: Total: 362.8 ± 119.10 Ga: 403 ± NR Gb: 410.0 ± 97.78 Gc: 357.6 ± 127.52 Gd: 331.4 ± 114.17 | Voids/day, mean ± SD: G1: 7.7 ± 1.87 G2: 7.6 ± 2.18 G1a: 6.1 ± NR G2a: 6.3 ± NR G1b: 7.3 ± 1.69 G2b: 7.0 ± 1.87 G1c: 7.5 ± 1.41 G2c: 7.2 ± 1.58 G1d: 8.3 ± 2.23 G2d: 8.4 ± 2.53 Volume (mL)/day, mean ± SD: G1: 1764.4 ± 333.03 G2: 1670.7 ± 338.6 G1a: 1862 ± NR G2a: 1720 ± NR G1b: 1715.6 ± 292.54 G2b: 1665.8 ± 251.19 G1c: 1847.9 ± 333.81 G2c: 1808.1 ± 317.59 G1d: 1694.7 ± 331.33 G2d: 1550.3 ± 373.65 Voided volume (mL), mean ± SD: G1: 239.9 ± 64.98 G2: 236.7 ± 63.03 G1a: 321 ± NR G2a: 286 ± NR G1b: 243.3 ± 59.56 G2b: 248.3 ± 53.91 G1c: 252.9 ± 55.75 G2c: 258.6 ± 60.63 G1d: 217.6 ± 67.07 G2d: 203.1 ± 55.43 Bladder volume (mL), first desire void, mean ± SD: G1: 129.0 ± 30.14 G2: 117.9 ± 27.62 G1a: 144 ± NR G2a: 140 ± NR G1b: 153.5 ± 25.72 G2b: 132.0 ± 31.01 G1c: 120.8 ± 25.07 G2c: 113.2 ± 23.16 G1d: 119.4 ± 29.43 G2d: 110.1 ± 26.15 G1/BL: P < 0.05 G2/BL: P < 0.05 Bladder volume (mL), first contraction, mean ± SD: G1: 212.9 ± 106.10 G2: 206.9 ± 103.56 G1a: 382 ± NR G2a: 364 ± NR G1b: 355.28 ± 74.79 G1c: 142.4 ± 43.51 G2c: 144.6 ± 48.43 G1d: 173.3 ± 57.37 G2d: 162.7 ± 53.87 G1d/BL: P < 0.01 G2d/BL: P < 0.01 Pressure (cmH_2_0), first contraction, mean ± SD: G1: 30.9 ± 22.63 G2: 30.9 ± 19.01 G1a: 14.0 ± NR G2a: 17.4 ± NR G1b: 35.6 ± 12.86 G2b: 29.6 ± 13.56 G1c: 17.2 ± 6.80 G2c: 17.9 ± 6.69 G1d: 42.9 ± 28.91 G2d: 44.1 ± 20.75 Overactivity index, mean ± SD: G1: 24.4 ± 22.61 G2: 24.7 ± 23.46 G1a: 7.0 ± NR G2a: 9.5 ± NR G1b: 14.1 ± 12.09 G2b: 14.1 ± 12.71 G1c: 18.3 ± 15.89 G2c: 16.9 ± 16.84 G1d: 38.9 ± 26.50 G2d: 40.7 ± 26.58 Cystometric capacity (mL), mean ± SD: G1: 419.3 ± 120.86 G2: 415.63 ± 114.06 G1a: 465 ± NR G2a: 453 ± NR G1b: 449.6 ± 106.23 G2b: 459.4 ± 101.17 G1c: 409.9 ± 130.22 G2c: 411.05 ± 132.49 G1d: 401.8 ± 118.34 G2d: 386.7 ± 96.53 Dry mouth, n (%): G1: 52 (40.6) G2: 20 (15.6) Constipation, n (%): G1: 11 (10.3) G2: 3 (2.8) Discontinued due to AEs, n: Dry mouth: 12 Palpitations: 1 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: + Masking: NA Pt selection criteria: + Loss to followup: ++ Drop-out rates: − Power calculation: − Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Gleason et al. 1999 Country and setting: US, Community Enrollment period: NR 12 week follow up Funding: Alza Corporation Author industry relationship disclosures: NR | Design: Multicenter Open label Single treatment Intervention: Oxybutynin ER Groups: G1: Oxybutynin ER 5– 30 mg/day (dose adjustment period) N at enrollment: G1: 256 N at follow-up: G1: 219 37 missing data 20 from AEs 4 dc’d lack of effectiveness, included in analysis Age, yrs ± SD: NR 38.8% were 65+ Race/ethnicity, n (%): White: G1: 235 (91.8) Women, N (%): G1: 234 (91.4) | Inclusion criteria: • ≥ adult men and women • Idiopathic urge incontinence • Mixed incontinence with clinically significant urge component Exclusion criteria: • Uncontrolled medical condition • PVR > 100 mL • Significant bacteruria • Significant pyuria | UUI episodes/week, mean ± SD: G1: 18.8 ± 1.2 Total incontinent episodes/week, mean ± SD: G1: 22.2 ± 1.3 Voids/week, mean ± SD: G1: 81.1 ± 1.8 PVR, mL, mean ± SD: G1: 17.4 ± 1.3 Voided volume, mL, ± SD: G1: 121 ± 79.1 | UUI episodes/week, mean ± SD: G1: 2.8 ± 0.6 P < 0.001 Total incontinent episodes/week, mean ± SD: G1: 4.0 ± 0.7 P < 0.001 Voids/week, mean ± SD: G1: 66.8 ± 1.4 Reduction Voids/week, mean ± SD: G1: 14.3 ± 1.3 95%CI: 11.7–16.8 PVR, mL, mean ± SD: G1: 21.0 ± 2.2 P = NR Voided volume, mL, ± SD: G1: 113.4 ± 84.6 P = NR Participants free UUI episodes, %: 55.7 Dry Mouth, n (%): G1: 128 (58.6) Discontinuation d/t AE, n (%): 20 (7.8) Nausea (%): 2.3 Dry Mouth (%): 1.6 Somnolence (%): 1.2 Urinary retention, n (%): 2 (0.8) Increased PVR, n, (%): 1 (0.4) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: + Drop-out rates: ++ Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Goode et al., 2002 Country and setting: US, academic health center outpatient geriatric medicine clinic Enrollment period: July 1989 to August 1995 Funding: National Institutes on Aging Author industry relationship disclosures: NR | Design: RCT, placebo controlled Computer-generated random numbers using a block size of 6, w/prior stratification by type and severity of incontinence Intervention: Biofeedback-assisted behavioral vs. drug treatment (oxybutynin chloride; possible range of doses 2.5 mg/d–5.0 mg t.i.d.) vs. placebo All patients had 4 visits over an 8-week period. Patients in G1 had biofeedback added to behavioral training in absence of 50% improvement by session 3. Groups: G1: Behavioral ± biofeedback G2: Pharmacologic G3: Placebo N at enrollment: 468 screened 271 not eligible 197 randomized 105 had pre and post treatment urodynamics G1: 33 G2: 35 G3: 37 N at follow-up: NA Age, yrs ± SD: G1: 65.3 ± 4.5 G2: 67.9 ± 7.9 G3: 67.6 ± 7.7 Race/ethnicity, %: Black: 2 White: 98 Women: 100% Parity mean ± SD: G1: 3.1 ± 1.7 G2: 2.1 ± 1.3 G3: 2.3 ± 1.5 | Inclusion criteria: • Community-dwelling women at least age 55 • Ambulatory • At least 2 urge accidents per week by baseline bladder diary • Urge incontinence as predominant pattern • Urodynamic evidence of bladder dysfunction Exclusion criteria: • Continual leakage • Postvoid residual urine volume >200mL • Uterine prolapse past the introitus • Narrow-angle glaucoma • Unstable angina • Decompensated congestive heart failure • History of malignant arrhythmias • MMSE <20 (Dementia) | Voids per day, mean ± SD: G1: 10.0 G2: 10.9 G3: 10.0 Cystometric volume (mL), first desire to void, mean ± SD: G1: 97.1 ± 50.7 G2: 101.1 ± 62.1 G3: 124.6 ± 73.7 Cystometric volume (mL), strong desire to void mean ± SD: G1: 188.5 ± 93.1 G2: 212.1 ± 86.7 G3: 222.3 ± 87.0 Cystometric volume (mL), bladder capacity, mean ± SD: G1: 288.3 ± 117.0 G2: 308.7 ± 93.7 G3: 328.9 ± 107.6 | Voids per day, mean ± SD: G1: 8.2 G2: 8.8 G3: 9.7 DI on UDS, n (%): +Baseline DI/+DI post-treatment: G1: 7 (21.2) G2: 1 (2.9) G3: 5 (13.5) +Baseline DI/−DI post-treatment: G1: 1 (3.0) G2: 7 (20.0) G3: 7 (18.9) −Baseline DI/+DI post-treatment: G1: 3 (9.1) G2: 3 (8.6) G3: 3 (8.1) −Baseline DI/−DI post-treatment: G1: 22 (66.7) G2: 24 (68.6) G3: 22 (59.5) Cystometric volume (mL), first desire to void, mean ± SD: G1: 115.9 ± 64.9 G2: 145.6 ± 74.0 G3: 133.5 ± 59.6 Cystometric volume (mL), strong desire to void mean ± SD: G1: 228.9 ± 106.4 G2: 282.0 ± 93.2 G3: 230.1 ± 78.8 Cystometric volume (mL), bladder capacity, mean ± SD: G1: 305.6 ± 117.9 G2: 377.6 ± 92.1 G3: 323.0 ± 109.0 Cystometric, volume (mL), first desire to void, mean change: G1: 18.8 G2: 44.4 G3: 8.9 P = 0.149 Cystometric, volume (mL), strong desire to void, mean change: G1: 40.5 G2: 69.9 G3: 7.8 P = 0.018 Cystometric, volume (mL), bladder capacity, mean change: G1: 17.3 G2: 68.9 G3: −6.0 P = 0.000 Standardized estimates of direct and mediated effects of treatment: G1/G3: Total effect: 0.28* Direct effect: 0.23 Mediated Effect: 0.05 G2/G3: Total Effect: 0.34* Direct Effect: 0.30* Mediated Effect: 0.04 *P < 0.01 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Haab et al., 2005 Country and setting: Multinational, Community Enrollment period: NR 52 week open enrollment Funding: Yamanouchi Author industry relationship disclosures: 1 of 4 Yamanouchi (1) | Design: Cohort open-label extension Intervention: Solifenacin 5mg for 4 weeks, then pt-selected dose of either 5 or 10 mg daily for remainder of study Groups: NA N at enrollment: 1,637 N at follow-up: 1,329 Women, n (%): 1,280 (78) Age, mean ± SD: 56.4 ± 13.5 Race/ethnicity, n (%): Black: 8 (0.5) White: 1,602 (98.1) Asian 13 (0.8) Other: 10 (0.6) Weight (kg), mean ± SD: 74.5 ± 14.6 Height (cm), mean ± SD: 165.3 ± 8.4 | Inclusion criteria: • Age ≥ 18 • Symptoms of OAB ≥ 3 months • ≥ 8 voids per day • ≥ 1 urgency episode/day • ≥ 1 UUI episodes/day • Completed treatment in previous RCT ≤ 14 days prior to extension study entry Exclusion criteria: • BOO • PVR > 200 mL • Persistent or recurrent UTI • Bladder stones • IC • Previous pelvic radiation • Previous or current pelvic organ malignancy • Narrow angle glaucoma • Gastric retention • Urinary retention • Pregnant/nursing • Non-reliable BC in childbearing woman | Urgency episodes/day, mean ± SD: 5.76 ± 4.46 Incontinence episodes/day, mean ± SD: 2.66 ± 2.51 Voids/day, mean ± SD: 12.16 ± 3.79 Nocturia episodes/day, mean ± SD: 1.95 ± 1.22 Voided volume (mL), mean ± SD: 147.6 ± 53.8 | Urgency episodes/day, mean ± SD (% change): 2.28 ± 3.59 (−63) Incontinence episodes/day, mean ± SD (% change): 0.93 ± 2.06 (−66) Voids/day, mean ± SD (% change): 9.18 ± 3.33 (−23) Nocturia episodes/day, mean ± SD (% change): 1.25 ± 1.26 (−32) Voided volume (mL), mean ± SD (% change): 187.4 ± 75.4 (31) Dry mouth, n (%): 339 (20.7) Constipation, n (%): 157 (9.6) Blurred vision, n (%): 113 (6.9) Discontinuation rate due to AE, %: 4.7 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: + Drop-out rates: ++ Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Haab et al., 2006 [See evidence table for Hill et al., 2007] Country and setting: France, Denmark, Sweden, Australia, Canada, US Enrollment period: NR Funding: Novartis Pharma AG (educational grant) Author industry relationship disclosures: 8 of 9 Astellas (1) Novartis (8) Pfizer (1) | Design: 2-year, non-comparative, open-label extension study Intervention: Darifenacin following 2 feeder studies of darifenacin 3.75/7.5/15 mg qd or placebo × 12 wks Groups: NA N at enrollment: 719 N at follow-up (%): 475 (66.3) Women, n (%): 609 (85.1) Age, mean (range): 57.3 (19–89) Age ≥ 65, %: 29.9 Race/ethnicity: NR Received treatment ≥ 365 days, n (%): 532 (74.3) | Inclusion criteria: • Successful completion of one of two previous, 12-wk feeder studies with no major protocol violation Exclusion criteria: NR | Urgency episodes/day, median (IQR): 8.1 (5.7–10.3) Urgency severity, VAS score, median (IQR): 54.7 (43.7–66.1) Incontinence episodes/week, median (IQR): 16.8 (10.0–27.0) Significant leaks/week, median (IQR): 7.0 (2.3–14.0) Voids/day, median (IQR): 10.1 (8.9–12.1) Nocturia episodes/week, median (IQR): 11.0 (7.0–16.0) Voided volume (mL), median (IQR): 163 (121–217) Primary diagnosis, n (%) Idiopathic: 674 (94.1) Neurogenic: 42 (5.9) Previous OAB drug treatment, n (%): 163 (22.8) | Urgency episodes/day, median change (median % change): −3.9 (−56.4) P < 0.001 Urgency severity, median change (median % change): −15.4 (−28.8) P < 0.001 Incontinence episodes/week, median change (median % change): −11.0 (−84.4) P < 0.001 Significant leaks/week, median change (median % change): −4.7 (−100.0) P < 0.001 Incontinence episodes, responders, reduction, %: ≥ 50%: 77.2 ≥ 70%: 62.3 ≥ 90%: 43.8 Voids/day, median change (median % change): −1.4 (−13.9) P < 0.001 Nocturia episodes/week, median change (median % change): −1.5 (−14.3) P < 0.001 Increased dose to 15 mg at 2 wks and maintained, n (%): 363 (50.7) Remained on 7.5 mg dose, n (%): 182 (25.4) Dose adjusted at other times, n (%): 171 (23.9) Compliance, ≥ 80% of doses, %: >85 Voided volume (mL), median change (median % change): 19.0 (11.9) P < 0.001 Adverse events, all causality, n (%): Any: 572 (79.9) Serious: 84 (11.7) Dry mouth: 167 (23.3) Constipation: 150 (20.9) UTI: 82 (11.5) Respiratory d/o: 76 (10.6) Dyspepsia: 65 (9.1) Accidental injury: 57 (8.0) ‘Flu’ syndrome: 49 (6.8) HA: 42 (5.9) HTN: 39 (5.4) Arthritis: 36 (5.0) Bronchitis: 34 (4.7) Arthralgia: 33 (4.6) Back pain: 30 (4.2) Increased cough: 26 (3.6) Arthrosis: 25 (3.5) Pain: 23 (3.2) Sinusitis: 22 (3.1) Adverse events, treatment related, n (%): Any: 343 (47.9) Serious: 1 (0.1) Dry mouth: 166 (23.2) Constipation: 142 (19.8) UTI: 8 (1.1) Respiratory d/o: 2 (0.3) Dyspepsia: 36 (5.2) Accidental injury: 1 (0.1) ‘Flu’ syndrome: 0 HA: 14 (2.0) HTN: 3 (0.4) Arthritis: 1 (0.1) Bronchitis: 0 Arthralgia: 1 (0.1) Back pain: 4 (0.6) Increased cough: 1 (0.1) Arthrosis: 0 Pain: 1 (0.1) Sinusitis: 1 (0.1) Days of bowel motions, mean change*: −0.04 Days of hard or lumpy bowel motions, mean change:* 0.13 Days of straining, mean change:* 0.22 Days of incomplete bowel openings:* 0.39 Days on which patient felt life was affected by bowel habits:* 0.17 Extent to which life affected by bowel habits in previous 2 wks, mean score:* 0.31 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: + Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Halaska et al., 2003 Country and setting: Europe and Asia, Academic medical center Enrollment period: May 1996 to May 1999 Funding: NR Author industry relationship disclosures: NR | Design: Randomized controlled double blind crossover Intervention: Trospium vs. Oxybutynin Groups: G1: Trospium 20 mg b.i.d. G2: Oxybutynin 5 mg b.i.d. N at enrollment: G1: 268 G2: 90 N at follow-up: G1: 200 G2: 66 Women, n (%): G1: 228 (85) G2: 78 (87) Age, mean (range): G1: 54.2 (19, 89) G2: 52.2 (19, 85) Weight (kg), mean (range): G1: 72.3 (50–120) G2: 70.4 (50–90) Height (cm), mean (range): G1: 164.8 (144–185) G2: 165.5 (145–183) Smokers, n (%): G1: 38 (14) G2: 10 (11) Previous illness, n (%): G1: 184 (69) G2: 66 (73) Previous medication, n (%): G1: 101 (38) G2: 46 (51) | Inclusion criteria: • Age ≥ 18 yrs • Urge syndrome • Urge incontinence • UUI as one component of MUI • UUI due to neurologic condition (detrusor hyperreflexia) Exclusion criteria: • Absolute tachycardia • Closed angle glaucoma • Myasthenia gravis • Arteriosclerosis of cerebral vessels • SUI • Heart or renal failure • Frequency from diuretics • BOO • Acute UTI • Hiatus hernia with reflux esophagitis • Stenosis of GI tract • Megacolon • Colonic ulceration • Allergy to study medications • Anticholinergics, TCAs, alpha blockers, beta sympatho-mimetics ≤ 7 days • Urological or gynecologic surgery ≤ 3 mos • Pregnant or lactating • In another study | Urgency episodes/day, mean: G1: 10.2 G2: 11.0 Incontinence episodes/day, mean: G1: 1.5 G2: 2.1 Voids/day, mean: G1: 11.4 G2: 12.5 Max cystometric capacity (mL), mean: G1: 205 G2: 205 | Urgency episodes/day, mean: G1: 6.7 G2: 7.4 Incontinence episodes/day, mean: G1: 0.5 G2: 1.1 Voids/day, mean: G1: 7.9 G2: 8.3 Max cystometric capacity (mL), 26 wks, mean change: G1: 92.0 G2: 117.0 G1/BL: P ≤ 0.001 G2/BL: P ≤ 0.001 Max cystometric capacity (mL), 52 wks, mean change: G1: 115.0 G2: 119.4 G1/BL: P ≤ 0.001 G2/BL: P ≤ 0.001 Bladder volume (mL), first contraction, 26 wks, mean change: G1: 63.5 G2: 61.2 Bladder volume (mL), first contraction, 52 wks, mean change: G1: 46.1 G2: 36.7 Bladder volume (mL), first sensation, 26 wks, mean change: G1: 73.6 G2: 76.93 Bladder volume (mL), first sensation, 26 wks, mean change: G1: 78.6 G2: 70.2 Abnormal EKG, n (%): G1: 4 (0.1) G2: 2 (0.2) Any adverse event, n (%): G1: 10 (3.7) G2: 6 (6.7) Poor efficacy, n (%): G1: 8 (3) G2: 2 (2.2) Poor compliance, n (%): G1: 15 (15.6) G2: 6 (6.7) Abdominal pain, n (%): G1: 5 (2) G2: 0 (0) Constipation, n (%): G1: 18 (7) G2: 4 (4) Diarrhea, n (%): G1: 2 (1) G2: 2 (2) Dyspepsia, n (%): G1: 13 (5) G2: 3 (3) Dysphagia, n (%): G1: 9 (3) G2: 3 (3) Dry mouth, n (%): G1: 87 (33) G2: 45 (50) P < 0.001 Nausea, n (%): G1: 6 (2) G2: 2 (2) UTI, n (%): G1: 33 (12) G2: 10 (11) Headache, n (%): G1: 11 (4) G2: 8 (9) Visual disturbances, n (%): G1: 9 (3) G2: 5 (6) Virus infection, n (%): G1: 9 (3) G2: 4 (4) Abnormal EKG, n (%): G1: 4 (0.1) G2: 2 (0.2) Sleeplessness, n (%): G1: 10 (4) G2: 2 (2) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: − Pt selection criteria: + Loss to followup: ++ Drop-out rates: ++ Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Herschorn et al., 2004 Country and setting: Canada, Family medicine and urology clinics Enrollment period: June 2000 to December 2001 Funding: Pharmacia Pfizer Canada Author industry relationship disclosures: NR | Design: RCT Intervention: Health education with tolterodine vs. tolterodine alone Groups: G1: Health education with tolterodine G2: tolterodine alone N at enrollment: G1: 39 G2: 45 N at follow-up, 5 weeks: G1: 37 G2: 40 N at follow-up, 10 weeks: G1: 35 G2: 32 N at follow-up, 16 weeks: G1: 34 G2: 31 Age, yrs ± SD: G1: 65.7 ± 14.5 G2: 63.1 ± 15.7 Race/ethnicity: NR Women, %: G1: 92.3 G2: 84.4 Parity: NR | Inclusion criteria: • Age ≥ 50 • Symptoms of OAB • Attend investigators’ practice • Normal cognitive function • Able to read English Exclusion criteria: • Enrollment in another clinical trial • Interstitial cystitis • UTI • Already taking tolterodine | OAB duration (yrs), mean ± SD: G1: 8.7 ± 11.0 G2: 8.7 ± 10.8 Mild bladder problems, n (%): G1: 13 (33.3) G2: 13 (28.9) Moderate bladder problems, n (%): G1: 19 (48.7) G2: 28 (62.2) Severe bladder problems, n (%): G1: 7 (18.0) G2: 4 (8.9) Obtained prescription, n (%): G1: 38 (97.4) G2: 37 (82.2) P < 0.05 Intends to fill prescription, (%): G1: 0 (0) G2: 6 (7.5) | Incontinence episodes/week, mean change ± SD: G1: −7.72 ± 21.16 G2: −10.24 ± 19.56† Voids/day, mean change ± SD: G1: −1.82 ± 3.41 G2: −2.18 ± 4.89 P = NR Nocturia episodes/day, mean change ± SD: G1: −0.44 ± 1.13† G2: −0.07 ± 0.91 No change in bladder problem severity, n (%): G1: 14 (42.4) G2: 20 (66.7) Improved bladder problem severity, n (%): G1: 15 (45.4)† G2: 6 (20) Worsened bladder problem severity, n (%): G1: 4 (12.1) G2: 4 (13.3) Compliance, 10 weeks, %: G1: 41 G2: 38 P > 0.05 Compliance, 16 weeks, %: G1: 39 G2: 31 P > 0.05 Continued or started non-drug OAB treatment, 16 weeks, %: G1: 82 G2: 53 P > 0.05 Stopped non-drug OAB treatments, %: G1: 12.8 G2: 28.9 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: − Masking: − Pt selection criteria: + Loss to followup: − Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: NR Baseline characteristics: − Length of followup: ++ Measurement methods: + Measurement reliability: − Intervention description: +
Author: Hill et al., 2006 Country and setting: Multinational- European; Community; 62 centers Enrollment period: NR Funding: Pfizer Novartis Thomson ACUMED Author industry relationship disclosures: NR | Design: RCT Intervention: Darifenacin vs. placebo Groups: G1: Darifenacin 7.5 mg daily G2: Darifenacin 15 mg daily G3: Darifenacin 30 mg daily G4: placebo N at enrollment: G1: 108 G2: 107 G3: 115 G4: 109 N at follow-up: G1: 99 G2: 93 G3: 96 G4: 101 Total 50 (11.4%) discontinued study- AE and withdrawal of consent Age, mean (range): G1: 56.1 (23–88) G2: 55.1 (24–82) G3: 54.0 (23–79) G4: 53.7 (21–85) Race/ethnicity: NR Women, N (%): G1: 94 (87) G2: 92 (86) G3: 99 (86) G4: 90 (83) Parity: NR Previous drug therapy, n (%): G1: 21 (19.4) G2: 22 (20.6) G3: 33 (28.7) G4: 24 (22.0) | Inclusion criteria: • Male and female • Age ≥18 • ≥ 10 episodes UUI over 14 days • ≥ 8 voids/day • ≥ 1 episode of urinary urgency • Symptoms OAB ≥ 6 months Exclusion criteria: • SUI • > 2 UTI/year • BOO • PVR> 200 • IC • Bladder stones • Severe constipation • History of intermittent UTI • Urogenital surgery within previous 6 months • Cystoscopy within previous 30 days • Indwelling catheter • CIC • Clinically significant systemic disease • Bladder training • CI to antimuscarinic therapy • Pregnant/lactating • Concomitant treatment with anticholinergic/antispasmodics, opioids, HRT, drugs that inhibit cytochrome P450, 2D6, and 3A4 isoenzymes | Urgency episodes/day, median (95% CI): G1: 8.5 (7.0, 8.7) G2: 8.6 (7.8, 9.4) G3: 8.4 (7.8, 8.8) G4: 8.1 (7.4, 8.7) Severity of urgency, visual analog scale (0=mild, 100= severe), (range): G1: 53.2 (50.1–56.5 G2: 55.8 (51.5–59.8) G3: 53.5 (50.0–57.9) G4: 53.5 (51.2–57.0) Incontinence episodes/week, median (95% CI): G1: 13.7 (11.8, 17.8) G2: 17.3 (13.5, 21.5) G3: 19.1 (15.8, 22.8) G4: 16.1 (14.0, 19.4) Voids/day, median (95% CI): G1: 10.3 (9.8, 10.9) G2: 11.0 (10.4, 12.1) G3: 10.4 (9.8, 11.4) G4: 10.1 (9.8, 10.8) Number OAB- related nocturnal awakenings/week, median (95 %CI): G1: 12.4 (10.2, 12.9) G2: 11.7 (9.8, 14.5) G3: 12.4 (10.5, 14.0) G4: 10.4 (9.2, 12.9) Voided volume (mL), median (95 %CI): G1: 162 (153, 181) G2: 157 (143, 173) G3: 156 (144, 168) G4: 162 (149, 174) | Urgency episodes/day, median change (%): G1: −1.8 (−29.2) G2: −2.3 (−26.9) G3: −3.0 (−33.1) G4: −1.2 (−15.7) G1/G4: P = 0.196 G2/G4: P = 0.013 G3/G4: P < 0.001 Severity of urgency, visual analog scale (0=mild, 100= severe), median change (range): G1: −7.0 (−14.2) G2: −7.0 (−11.6) G3: −9.4 (−19.9) G4: −3.9 (−8.0) G1/G4: P = 0.177 G2/G4: P = 0.045 G3/G4: P = 0.011 Incontinence episodes/wk, median change (%): G1: −8.1 (−68.7) G2: −10.4 (−76.5) G3: −11.4 (−77.3) G4: −5.9 (−46.0) G1/G4: P = 0.007 G2/G4: P < 0.001 G3/G4: P < 0.001 Leaks/week, median change (%): G1: −4.3 (−67.0) G2: −5.3 (−76.7) G3: −6.0 (−73.7) G4: −2.4 (−43.2) G1/G4: P = 0.012 G2/G4: P < 0.001 G3/G4: P < 0.001 Patients achieving ≥7 consecutive days “dry”, (%): G1: NR G2: 28 G3: 30 G4: 17 G2/G4: P = 0.29 G3/G4: P = 0.011 Voids/day, median change (%): G1: −1.7 (−16.7) G2: −1.9 (−17.9) G3: −2.2 (−21.2) G4: −1.1 (−9.6) G1/G4: P = 0.06 G2/G4: P = 0.033 G3/G4: P < 0.001 Number OAB- related nocturnal awakenings/week, median change (%): G1: −1.9 (−22.1) G2: −1.7 (−22.7) G3: −2.0 (−19.2) G4: −0.4 (−3.6) G1/G4: P = 0.028 G2/G4: P = 0.022 G3/G4: P = 0.008 Voided volume (mL), median change (%): G1: 17 (10.3) G2: 24 (15.6) G3: 44 (26.0) G4: 7 (4.1) G1/G4: P = 0.079 G2/G4: P = 0.001 G3/G4: P < 0.001 Dry mouth, n (%): G1: 25 (23.1) G2: 43 (40.2) G3: 68 (59.1) G4: 6 (5.5) Constipation, n (%): G1: 17 (15.7) G2: 27 (25.2) G3: 32 (27.8) G4: 5 (4.6) Dyspepsia, n (%): G1: 4 (3.7) G2: 9 (8.4) G3: 10 (8.7) G4: 1 (0.9) Headache, n (%): G1: 7 (6.5) G2: 7 (6.5) G3: 7 (6.1) G4: 2 (1.8) Respiratory tract infection, n (%): G1: 4 (3.7) G2: 6 (5.6) G3: 1 (0.9) G4: 6 (5.5) Urinary tract disorder, n (%): G1: 0 (0) G2: 6 (5.6) G3: 1 (0.9) G4: 0 UTI, n (%): G1: 3 (2.8) G2: 3 (2.8) G3: 5 (4.3) G4: 2 (1.8) Flu syndrome, n (%): G1: 3 (2.8) G2: 2 (1.9) G3: 0 G4: 5 (4.6) Back pain, n (%): G1: 3 (2.8) G2: 1 (0.9) G3: 5 (4.3) G4: 3 (2.8) Abdominal pain, n (%): G1: 1 (0.9) G2: 3 (2.8) G3: 4 (3.5) G4: 1 (0.9) Abnormal vision, n (%): G1: 2 (1.9) G2: 0 G3: 4 (3.5) G4: 0 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Hill et al., 2007 [See evidence table for Haab et al., 2006] Country and setting: France, Denmark, Sweden, Australia, Canada, US, Multicenter Enrollment period: NR Funding: Novartis Pharma AG (educational grant) Author industry relationship disclosures: NR | Design: 2-yr, non-comparative, open-label extension study Intervention: Darifenacin following 2 feeder studies of darifenacin 3.75/7.5/15 mg qd or placebo x 12 wks Groups: NA N at enrollment: 214 N at follow-up (%): 137 (64.0) Patient years of exposure: 308 Women, n (%): 172 (80.4) Age, n (%): 65–74 years: 166 (77.6) 75–89 years: 48 (22.4) Race/ethnicity: NR Menopausal, n (%): 13 (6.1) | Inclusion criteria: • Age ≥ 65 • Successful completion of one of 2 previous, 12-wk feeder studies with no major protocol violation Exclusion criteria: NR | Urgency episodes/day, median: 8.1 Urgency severity, median VAS score: 51.8 Incontinence episodes/week, median: 18.7 Voids/day, median: 10.1 Voided volume (mL), median: 156 Concomitant drug treatment, n (%): 210 (98.1) | Urgency episodes/day, median change (median % change): −3.7 (−52.0) P < 0.05 Urgency severity, VAS score, median change (median % change): −12.6 (−23.3) P < 0.05 Incontinence episodes/week, median change (median % change): −11.0 (−83.7) P < 0.05 Significant leaks/week, median change (median % change): −4.9 (−100.0) P < 0.05 Incontinence episodes, responders, % reduction, %: ≥ 50%: 74.1 ≥ 70%: 60.0 ≥ 90%: 44.4 Voids/day, median change (median % change): −1.2 (−12.4) P < 0.05 Normalization of voiding frequency (< 8 voids/day) after darifenacin treatment, %: 3 months: 34 2 years: 33.8 Nocturia episodes/week, median change (median % change): −1.4 (−10.9) G1/BL: P < 0.05 Increased dose to 15 mg at 2 wks and maintained, n (%): 110 (51.4) Remained on 7.5 mg dose, n (%): 55 (25.7) Dose adjusted at other times, n (%): 49 (22.9) Compliance, ≥ 80% of doses, n (%): 214 (84) Voided volume (mL), median change (median % change): 11.1 (6.3) Dry mouth, n (%): 50 (23.4) Constipation, n (%): 48 (22.4) CVD, %: 1.4 Peripheral/CNS, %: 3.3 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: + Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Homma and Koyama, 2006 Country and setting: Japan, Community Enrollment period: NR 9 weeks 1 week wash out 8 week treatment Funding: Sanyko Company Author industry relationship disclosures: 1 of 2 Sanyko (1) | Design: RCT Intervention: Oxybutynin Transdermal (TDS) patch vs placebo Groups: G1: OXY TDS 26 cm^2^ G2: OXY TDS 39 cm^2^ G3: OXY TDS 52 cm^2^ G4: placebo N at enrollment: G1: 160 G2: 164 G3: 152 G4: 161 N at follow-up: G1: 160 G2: 164 G3: 152 G4: 161 Women, n (%): G1: 122 (76.3) G2: 132 (80.5) G3: 119 (78.3) G4: 117 (72.7) Age, mean ± SD: G1: 63.5 ± 11.5 G2: 62.7 ± 12.4 G3: 62.0 ± 13.6 G4: 62.9 ± 12.3 Race/ethnicity: NR | Inclusion criteria: • Adult with OAB syndrome • ≥ 1 episodes UUI per day • ≥ 8 voids per day Exclusion criteria: NR | Incontinence episodes/week, mean ± SD: G1: 21.1 ± 13.9 G2: 20.8 ± 14.6 G3: 20.4 ± 14.1 G4: 21.1 ± 16.6 KHQ, general health, mean ± SD: G1: 36.9 ± 21.0 G2: 38.6 ± 20.3 G3: 36.0 ± 21.4 G4: 36.0 ± 20.5 KHQ, incontinence impact, mean ± SD: G1: 54.6 ± 27.1 G2: 54.9 ± 26.7 G3: 57.1 ± 27.4 G4: 54.0 ± 25.5 KHQ, role limitation, mean ± SD: G1: 42.5 ± 24.6 G2: 40.7 ± 24.5 G3: 41.8 ± 26.5 G4: 43.0 ± 25.1 KHQ, physical limitation, mean ± SD: G1: 48.6 ± 26.0 G2: 45.8 ± 26.0 G3: 48.9 ± 29.6 G4: 46.9 ± 26.2 KHQ, social limitation, mean ± SD: G1: 27.4 ± 23.7 G2: 25.2 ± 24.3 G3: 26.1 ± 24.5 G4: 26.3 ± 25.7 KHQ, personal relationship, mean ± SD: G1: 17.9 ± 21.6 G2: 13.2 ± 20.7 G3: 16.4 ± 23.4 G4: 17.0 ± 24.7 KHQ, emotions, mean ± SD: G1: 45.3 ± 28.9 G2: 46.5 ± 27.3 G3: 46.1 ± 28.1 G4: 46.2 ± 26.2 KHQ, sleep/energy, mean ± SD: G1: 32.0 ± 25.4 G2: 35.3 ± 24.9 G3: 33.4 ± 28.5 G4: 32.5 ± 26.3 | Incontinence episodes/week, mean ± SD: G1: 10.3 ± 17.8 G2: 6.3 ± 10.4 G3: 8.9 ± 15.8 G4: 11.0 ± 15.4 G2/G4: P = 0.014 KHQ domain, general health, mean ± SD: G1: 33.4 ± 20.3 G2: 30.9 ± 22.2 G3: 33.9 ± 21.6 G4: 33.0 ± 22.7 G2/G4: P < 0.05 KHQ domain, incontinence impact, mean ± SD: G1: 34.6 ± 23.2 G2: 32.7 ± 23.6 G3: 34.0 ± 24.4 G4: 39.7 ± 26.0 G2/G4: P < 0.05 KHQ domain, role limitation, mean ± SD: G1: 24.8 ± 22.0 G2: 22.0 ± 20.3 G3: 26.5 ± 24.7 G4: 31.9 ± 24.1 G2/G4: P < 0.05 KHQ domain, physical limitation, mean ± SD: G1: 29.7 ± 25.6 G2: 26.6 ± 22.8 G3: 29.7 ± 27.3 G4: 36.5 ± 27.5 G2/G4: P < 0.05 KHQ domain, social limitation, mean ± SD: G1: 16.3 ± 21.3 G2: 13.2 ± 17.1 G3: 18.4 ± 22.8 G4: 21.6 ± 24.2 G2/G4: P < 0.05 KHQ domain, personal relationship, mean ± SD: G1: 10.4 ± 17.3 G2: 8.4 ± 16.8 G3: 11.6 ± 22.1 G4: 12.0 ± 20.2 G2/G4: P < 0.05 KHQ domain, emotions, mean ± SD: G1: 28.2 ± 25.8 G2: 24.9 ± 21.6 G3: 29.3 ± 26.7 G4: 35.2 ± 28.4 G2/G4: P < 0.05 KHQ domain, sleep/energy, mean ± SD: G1: 18.2 ± 19.2 G2: 17.9 ± 18.9 G3: 21.1 ± 22.8 G4: 26.0 ± 25.6 G2/G4: P < 0.05 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: − Masking: + Pt selection criteria: + Loss to followup: ++ Drop-out rates: NA Power calculation: − Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: + Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Jacquetin and Wyndaele, 2001 Country and setting: France (22 centers) and Belgium (10 centers) Enrollment period: NR Funding: Pharmacia Author industry relationship disclosures: NR | Design: Double-blind, placebo-controlled, parallel-group, multicenter phase III study w/2-wk washout period Intervention: Tolterodine vs placebo for 4 weeks Groups: G1: Tolterodine 2mg b.i.d. G2: Tolterodine 1 mg b.i.d. G3: placebo (frequency NR) N at enrollment: NR N at follow-up: G1: 103 G2: 97 G3: 51 Women, n (%): G1: 84 (82) G2: 74 (76) G3: 41 (80) Age, mean (range): G1: 58 (21–88) G2: 53 (18–85) G3: 56 (19–89) Race/ethnicity: NR BMI, kg/m^2^ (range): G1: 26.4 (17.7–39.7) G2: 25.5 (16.7–46.3) G3: 24.8 (17.6–36.9) | Inclusion criteria: • Age ≥ 18 • UDS-verified detrusor overactivity • ≥ 1 UUI episode/day • ≥ 8 voids/day Exclusion criteria: • SI • Hepatic or renal dz • +UTI or recurrent UTIs • Interstitial cystitis • Hematuria • Clinically significant voiding difficulty • Pts receiving bladder training, electrostimulation therapy • Indwelling catheter • Intermittent cath • Pregnant or nursing • Women of childbearing age w/o reliable contraception | UUI, n (%) G1: 75 (73) G2: 75 (77) G3: 39 (76) UUI episodes/day, mean (range): G1: 3.2 (0.1–24.0) G2: 2.7 (0.1–24.0) G3: 2.4 (0.1–8.4) Voids/day, mean (range): G1: 10.8 (6.2–34.7) G2: 10.7 (4.9–26.4) G3: 11.7 (6.3–26.3) ≥ 8 voids/day, n (%): G1: 96 (93) G2: 89 (92) G3: 49 (96) Urinary symptoms > 5 years, n (%): G1: 46 (45) G2: 42 (43) G3: 17 (33) Previous lower urinary tract surgery, n (%): G1: 36 (35) G2: 29 (30) G3: 16 (31) Previous drug therapy for OAB, n (%): G1: 66 (64) G2: 59 (61) G3: 36 (71) Previous poor efficacy response, n (%): G1: 50 (76) G2: 45 (76) G3: 26 (72) Voided volume (mL), mean (range): G1: 158 (43–382) G2: 150 (46–320) G3: 148 (23–284) | UUI episodes/day, mean change ± SD: G1: −1.3 ± 1.8 G2: −1.1 ± 2.2 G3: −0.4 ± 1.9 G1/G3: P = 0.0089 G2/G3: P = 0.045 Voids/day, mean change ± SD: G1: −1.4 ± 4.3 G2: −1.4 ± 2.8 G3: −1.2 ± 2.7 G1/G3: P = NS G2/G3: P = NS Good efficacy response in current study, previous poor efficacy response, n/N (%) G1: 20/39 (51) G2: 18/37 (49) G3: 7/19 (37) G1/G3: P = NS G2/G3: P = NS Voided volume (mL), mean change ± SD: G1: 19 ± 46 G2: 20 ± 42 G3: 7 ± 40 G1/G3: P = 0.056 G2/G3: P = 0.055 Dry mouth, n (%): G1: 35 (34) G2: 20 (21) G3: 3 (6) G1/G2: P < 0.05 G1/G3: P < 0.05 G2/G3: P < 0.05 Abdominal pain, n (%): G1: 4 (4) G2: 6 (6) G3: 2 (4) Constipation, n (%): G1: 2 (2) G2: 4 (4) G3: 2 (4) Headache, n (%): G1: 3 (3) G2: 3 (3) G3: 2 (4) Total AEs reported, n: G1: 84 G2: 78 G3: 26 Any AE, n (%): G1: 55 (53) G2: 39 (40) G3: 16 (31) G1/G3: P < 0.05 Discontinued due to AEs, n (%):* G1: 2 (2) G2: 3 (3) G3: 1 (2) | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: - Masking: + Pt selection criteria: + Loss to followup: NR Drop-out rates: ++ Power calculation: + Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: - Measurement methods: + Measurement reliability: + Intervention description: +
Author: Jarvis et al., 1981 Country and setting: UK, Academic medical center Enrollment period: NR Funding: NR Author industry relationship disclosures: NR | Design: RCT Intervention: Inpatient bladder drill vs outpatient drug therapy Groups: G1: inpatient bladder drill G2: flavoxate hydrochloride 200 mg tds and imipramine 25 mg tds x 4 wks N at enrollment: G1: 25 G2: 25 N at follow-up: G1: 25 G2: 25 Women, %: 100 Age, mean ± SD (range): G1: 47 ± 15.4 (17–78) G2: 46 ± 12.8 (17–65) | Inclusion criteria: • Women • UDS-diagnosed detrusor instability Exclusion criteria: • DM • Neurological abnormalities • UTIs • Taking a drug suspected of affecting lower urinary tract function • Genuine stres incontinence | UUI, n: G1: 25 G2: 25 SUI, n: G1: 19 G2: 17 Urgency, n: G1: 25 G2: 25 Frequency, n: G1: 25 G2: 25 Nocturia, n: G1: 21 G2: 19 Duration of symptoms (years), mean ± SD (range): G1: 4.3 ± 2.7 (1–15) G2: 5.4 ± 3.2 (1–20) Bladder volume (mL), first sensation, mean: G1: 87 G2: 79 Max cystometric capacity (mL), mean: G1: 381 G2: 353 | UUI, n: G1: 4 G2: 11 SUI, n: G1: 1 G2: 9 Urgency, n: G1: 4 G2: 11 Frequency, n: G1: 6 G2: 12 Nocturia, n: G1: 4 G2: 13 Continent, n (%): G1: 21 (84) G2: 14 (56) P < 0.05 Symptom-free, n (%): G1: 19 (76) G2: 12 (48) P < 0.05 Bladder volume (mL), first sensation, mean: G1: 152 G2: 140 Max cystometric capacity (mL), mean: G1: 470 G2: 446 Adverse events, drug therapy, n:* Dizziness: 8 Headache: 6 Dry mouth: 6 Nausea: 4 Drowsiness: 2 Vomiting: 1 Discontinued due to AEs, n: Dizziness: 1 Headache: 1 Vomiting: 1 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: - Masking: - Pt selection criteria: - Loss to followup: ++ Drop-out rates: ++ Power calculation: - Statistical issues: - EXTERNAL VALIDITY: poor Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: - Measurement reliability: - Intervention description: -
Author: Jonas et al., 1997 Country and setting: Austria, Germany, Sweden, Academic medical center Enrollment period: NR 1–2 week washout-run in to total 4 weeks efficacy/tolerability Funding: NR Author industry relationship disclosures: NR | Design: RCT Intervention: Tolterodine 1 mg b.i.d. vs tolterodine 2 mg b.i.d. vs placebo Groups: G1: Tolterodine 1 mg b.i.d. G2: Tolterodine 2mg b.i.d. G3: placebo N at enrollment: G1: 99 G2: 99 G3: 44 N at follow-up: G1: 98 G2: 99 G3: 44 Women, n (%): G1: 73 (74) G2: 76 (77) G3: 33 (75) Age, mean (range): G1: 59 (21, 81) G2: 57 (20, 83) G3: 57 (23, 92) Race/ethnicity: NR | Inclusion criteria: • Age ≥18 • Detrusor overactivity (phasic activity of amplitude of ≥ 10 cm H20 or 1 strong detrusor contraction that caused end of infusion) • ≥ 8 voids/day and ≥ 1 incontinence episode/day, urinary urgency, or both Exclusion criteria: • SUI • Hepatic disease • Renal disease • Any condition contraindicating anticholinergic activity • Indwelling catheter • Recurrent UTI • IC • Uninvestigated hematuria • Voiding difficulty at risk for urinary retention • Patients on anticholinergic therapy • Electrostimulation therapy or bladder training within 14 days prior to enrollment | Urinary incontinence, n (%): G1: 79 (80) G2: 83 (84) G3: 38 (86) Voids/day, mean (range): G1: 11.7 (0.0, 25.9) G2: 11.2 (4.1, 23.4) G3: 12.2 (7.3, 22.0) ≥ 8 voids/day, n (%): G1: 94 (95) G2: 91 (92) G3: 42 (96) Volume (mL), first contraction, mean ± SD: G1: 142 ± 102 G2: 141 ± 102 G3: 140 ± 86 Maximal height of wave (cmH_2_O), mean ± SD: G1: 41 ± 34 G2: 52 ± 43 G3: 47 ± 34 Max cystometric capacity (mL), mean ± SD: G1: 276 ± 142 G2: 272 ± 136 G3: 264 ± 116 Postvoid residual volume (mL), mean ± SD: G1: 25 ± 45 G2: 28 ± 47 G3: 38 ± 53 DO ≥ 10 cmH_2_O, n (%): G1: 99(100) G2: 97 (98) G3: 44 (100) | Volume (mL), first contraction, mean ± SD: G1: 210 ± 163 G2: 230 ± 160 G3: 181 ± 142 G1/G3: P = 0.22 G2/G3: P = 0.030 G1/BL: P < 0.001 G2/BL: P < 0.001 G3/BL: P = 0.11 Maximal height of wave (cmH_2_O), mean ± SD: G1: 35 ± 36 G2: 37 ± 38 G3: 40 ± 36 G1/G3: P = 0.97 G2/G3: P = 0.17 G1/BL: P = 0.007 G2/BL: P < 0.001 G3/BL: P = 0.11 Max cystometric capacity (mL), mean ± SD: G1: 294 ± 151 G2: 316 ± 156 G3: 268 ± 135 G1/G3: P = 0.43 G2/G3: P = 0.034 G1/BL: P = 0.36 G2/BL: P < 0.001 G3/BL: P = 0.80 Postvoid residual volume (mL), mean ± SD: G1: 35 ± 52 G2: 46 ± 70 G3: 41 ± 62 G1/G3: P = 0.034 G2/G3: P = 0.042 G1/BL: P = 0.063 G2/BL: P = 0.0076 G3/BL: P = 0.99 Dry mouth, n (%): G1: 8 (8) G2: 10 (10) G3: 1 (2) Dry mouth, mild, n (%): G1: 5 (5) G2: 7 (7) G3: 1 (2) Dry mouth, moderate, n (%): G1: 3 (3) G2: 2 (2) G3: 0 (0) Dry mouth, severe, n (%): G1: 0 (0) G2: 1 (1) G3: 0 (0) UTI, n (%): G1: 5 (5) G2: 2 (2) G3: 2 (5) Accomodation abnormal, n (%): G1: 3 (3) G2: 5 (5) G3: NA Constipation, n (%): G1: 2 (2) G2: 3 (3) G3: 2 (5) Headache, n (%): G1: 3 (3) G2: 3 (3) G3: 1 (2) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: - Masking: + Pt selection criteria: + Loss to followup: NR Drop-out rates: + Power calculation: - Statistical issues: - EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Karram et al., 2009 Country and setting: USA, multicenter (61 sites) Enrollment period: NR Funding: Astellas Pharma US, Glaxo-SmithKline Author industry relationship disclosures: NR | Design: RCT Intervention: Solifenacin 5 or 10 mg daily Groups: G1: solifenacin 5 mg daily (with dose adjustment at weeks 4 and 8) G2: placebo N at enrollment: G1: 372 G2: 367 N at follow-up (%): G1: 357 G2: 350 Age, mean: Total: 57 Race/ethnicity, %: White: Total: 83.5 Women, %: Total: 84.2 | Inclusion criteria: • Age ≥ 18 • OAB symptoms • ≥ 1 Urgency episode/day with or without leakage • >8 voids/day • ± nocturia Exclusion criteria: • SUI • MUI with primary stress • UTI • Chronic bladder inflammation • Bladder stones • Bladder cancer • Severe constipation • Narrow angle glaucoma • Urinary retention • Gastric retention • Hypersensitivity to drugs • BOO | Urgency episodes/day, mean ± SD: G1: 6.15 ± 3.92 G2: 6.03 ± 3.90 Warning time (sec), mean ± SD: G1: 136.4 ± 224.2 G2: 161.6 ± 333.9 Incontinence episodes/ day, mean ± SD: G1: 2.82 ± 2.70 G2: 2.56 ± 2.72 Voids/day, mean ± SD G1: 11.65 ± 3.72 G2: 11.70 ± 3.62 | Urgency episodes/day, mean ± SD: G1: 2.24 ± 3.04 G2: 3.30 ± 3.84 Urgency episodes/day, mean change ± SD: G1: −3.91 ± 3.54 G2: −2.73 ± 3.84 P < 0.0001 Warning time (sec), mean change ± SD: G1: 186.4 ± 600.7 G2: 54.7 ± 393.5 P = 0.008 Incontinence episodes/day, mean ± SD: G1: 0.72 ± 1.45 G2: 1.32 ± 2.65 Incontinence episodes, mean change ± SD: G1: −2.10 ± 2.39 G2: −1.24 ± 2.30 P < 0.0001 Voids/day, mean ± SD: G1: 8.98 ± 3.26 G2: 9.76 ± 3.50 Voids/day, mean change ± SD: G1: −2.67 ± 3.31 G2: −1.94 ± 3.30 P = 0.0014 Dry Mouth, %: G1: 25.3 G2: 9.0 Constipation, %: G1: 14.8 G2: 9.3 Blurred vision, %: G1: 3.8 G2: 1.1 Headache, %: G1: 4.6 G2: 5.2 Dizziness, %: G1: 3.2 G2: 1.9 Fatigue, %: G1: 2.7 G2: 1.1 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Method and blinding: + Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Kelleher, Reese et al., 2002* Kelleher, Kreder, et al., 2002 [See evidence table for Van Kerrebroeck, et al., 2001] Country and setting: Multinational: Europe North America Australia/New Zealand Russia/Ukraine, Community Enrollment period: NR 12 week 12 month† Funding: Pharmacia Corporation Author industry relationship disclosures: NR | Design: Randomized placebo-controlled double blind parallel-group; Open label uncontrolled non-randomized extension† Intervention: Tolterodine ER vs placebo Groups: G1: Tolterodine ER 4mg daily G2: placebo G3: Tolterodine IR 2mg b.i.d.* N at enrollment: G1: 507 G2: 508 G3: 514 N at follow-up: G1: 450 G2: 440 G3: 447 Women, n (%): Total: 827 (81.5) G1: 417 (82.2) G2: 410 (80.7)* G3: 408 (79.4)* Age, mean ± SD: G1: 60.3 ± 14.4 G2: 61.1 ± 13.9 G3: 60.0 ± 14.3* Race/ethnicity: NR Extension:† Tolterodine ER 4mg daily Groups:† G4: KHQ G5: SF-36 N at enrollment:† Total: 1077 N at follow-up:† G4: 838 G5: 961 Women, n (%):† G4: 678 (80.9) G5: 793 (82.5) Age, yrs ± SD:† G4: 61.1 ± 13.5 G5: 60.2 ± 13.7 Race/ethnicity, n, (%):† White: G4: 800 (95.5) G5: 927 (96.5) Black: G4: 28 (3.3) G5: 25 (2.5) Asian or Pacific: G4: 6 (0.7) G5: 6 (0.6) Mixed: G4: 4 (0.5) G5: 4 (0.4) | Inclusion criteria: • Age ≥ 18 • ≥ 8 voids/day on 7 day voiding diary • ≥ 5 UUI episodes/ week • OAB symptoms for at least 6 months Exclusion criteria: NR | NR | Patient rating of bladder condition, improvement, %: G1: 43 G2: 58 P = 0.001 Patient rating of bladder condition, deterioration, %: G1: 13 G2: 7 P = 0.004 KHQ, incontinence impact, mean change ± SD: G1: −15.68 ± 29.36 G2: −8.86 ± 26.65 P = 0.001 KHQ, incontinence impact, 12 months, mean change (SE):† G4: −23.1 (1.1) P = 0.002 KHQ, role limitations, mean change ± SD: G1: −17.93 ± 30.58 G2: −10.26 ± 29.20 P = 0.001 KHQ, role limitations, 12 months, mean change (SE):† G4: −23.8 (1.1) P = 0.002 KHQ, physical limitations, mean change ± SD: G1: −15.60 ± 29.98 G2: −8.73 ± 27.90 P = 0.001 KHQ, physical limitations, 12 months, mean change (SE):† G4: −19.9 (1.1) P = 0.002 KHQ, social limitations, mean change ± SD: G1: −8.49 ± 23.24 G2: −6.25 ± 22.76 P = 0.062 KHQ, social limitations, 12 months, mean change (SE):† G4: −11.5 (0.8) P = 0.002 KHQ, personal relationships, mean change ± SD: G1: −5.66 ± 26.74 G2: −3.44 ± 23.15 P = 0.446 KHQ, personal relationships, 12 months, mean change (SE):† G4: −8.4 (1.2) P = 0.002 KHQ, emotions, mean change ± SD: G1: −9.31 ± 24.85 G2: −6.52 ± 23.98 P = 0.106 KHQ, emotions, 12 months, mean change (SE):† G4: −13.8 (0.9) P = 0.002 KHQ, sleep and energy, mean change ± SD: G1: −9.82 ± 24.45 G2: −5.08 ± 21.06 P = 0.006 KHQ, sleep and energy, 12 months, mean change (SE):† G4: −11.7 (0.8) P = 0.002 KHQ, severity (coping) measures, mean change ± SD: G1: −11.98 ± 22.04 G2: −6.12 ± 20.39 P = 0.001 KHQ, severity (coping) measures, 12 months, mean change (SE):† G4: −13.8 (0.8) P = 0.002 KHQ, general health perception, mean change ± SD: G1: −0.41 ± 17.55 G2: −0.12 ± 17.49 P = 0.900 KHQ, general health perception, 12 months, mean change ± SD:† G4: −0.1 (0.6) P = 0.8302 KHQ, symptom severity, mean change ± SD: G1: −2.90 ± 4.10 G2: −1.42 ± 3.99 P = 0.001 KHQ, symptom severity, 12 months, mean change (SE):† G4: −11.7 (0.5) P = 0.002 SF-36, physical summary, mean change ± SD: G1: 0.97 ± 7.34 G2: 0.72 ± 6.57 P = 0.451 SF-36, mental summary, mean change ± SD: G1: 0.67 ± 8.63 G2: 0.10 ± 8.43 P = 0.684 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: − Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: − Power calculation: − Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: NR Baseline characteristics: − Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Kelleher et al., 2005 [See evidence table for Chapple et al., 2004 and Cardozo et al. 2004] Country and setting: Multinational, multicenter Enrollment period: NR Funding: NR Author industry relationship disclosures: 1 of 5 Pfizer (1) Yamanouchi (1) Lilly (1) Novartis (1) Q Med (1) | Design: Pooled analysis from the 40-wk open-label extension studies of 2 12-wk multinational, multicentre, double-blind RCTs Intervention: Solifenacin 5 mg vs solifenacin 10 mg vs placebo Groups: G1: solifenacin 5 mg qd G2: solifenacin 10 mg qd G2: placebo qd N at enrollment: 1637 N at follow-up: 1347 | Inclusion criteria: [See evidence table for Chapple et al., 2004 and Cardozo et al. 2004] Exclusion criteria: [See evidence table for Chapple et al., 2004 and Cardozo et al. 2004] | [See evidence table for Chapple et al., 2004 and Cardozo et al. 2004] | KHQ, general health perception, 12 weeks, mean change: G1: −4.3 G2: −4.0 G3: −2.3 G1/G3: P < 0.001 G2/G3: P = 0.031 KHQ, incontinence impact, 12 weeks, mean change: G1: −24.7 G2: −27.3 G3: −18.2 G1/G3: P < 0.001 G2/G3: P < 0.001 KHQ, role limitations, 12 weeks, mean change: G1: −20.6 G2: −22.7 G3: −15.4 G1/G3: P < 0.001 G2/G3: P < 0.001 KHQ, physical limitations, 12 weeks, mean change: G1: −17.7 G2: −20.3 G3: −13.7 G1/G3: P = 0.002 G2/G3: P < 0.001 KHQ, social limitations, 12 weeks, mean change: G1: −11.3 G2: −11.7 G3: −7.8 G1/G3: P = 0.003 G2/G3: P = 0.015 KHQ, personal relationships, 12 weeks, mean change: G1: −8.7 G2: −9.3 G3: −9.7 G1/G3: P = 0.650 G2/G3: P = 0.747 KHQ, emotions, 12 weeks, mean change: G1: −16.0 G2: −17.7 G3: −12.3 G1/G3: P < 0.001 G2/G3: P < 0.001 KHQ, sleep/energy, 12 weeks, mean change: G1: −13.8 G2: −14.4 G3: −10.0 G1/G3: P = 0.002 G2/G3: P = 0.001 KHQ, severity measures, 12 weeks, mean change: G1: −10.5 G2: −13.2 G3: −7.3 G1/G3: P < 0.001 G2/G3: P < 0.001 KHQ, symptom severity, 12 weeks, mean change: G1: −3.4 G2: −3.6 G3: −2.6 G1/G3: P < 0.001 G2/G3: P < 0.001 KHQ, general health perception, 40 weeks, mean change: G1: −6.0 G2: −7.1 G3: −7.8 KHQ, incontinence impact, 40 weeks, mean change: G1: −33.5 G2: −35.3 G3: −32.9 KHQ, role limitations, 40 weeks, mean change: G1: −29.1 G2: −28.9 G3: −30.8 KHQ, physical limitations, 40 weeks, mean change: G1: −25.7 G2: −27.0 G3: −26.0 KHQ, social limitations, 40 weeks, mean change: G1: −15.6 G2: −18.1 G3: −15.7 KHQ, personal relationships, 40 weeks, mean change: G1: −14.1 G2: −15.0 G3: −13.2 KHQ, emotions, 40 weeks, mean change: G1: −22.2 G2: −24.8 G3: −21.0 KHQ, sleep/energy, 40 weeks, mean change: G1: −17.9 G2: −19.5 G3: −18.8 KHQ, severity measures, 40 weeks, mean change: G1: −15.3 G2: −17.2 G3: −14.7 KHQ, symptom severity, 40 weeks, mean change: G1: −4.4 G2: −4.7 G3: −4.7 | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: − Masking: + Pt selection criteria: + Loss to followup: ++ Drop-out rates: ++ Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Koonings et al., 1991 Country and setting: US, Academic medical center Enrollment period: January 1986 to October 1987 Funding: NR Author industry relationship disclosures: NR | Design: Cohort Intervention: Oxybutynin chloride 5 mg t.i.d. × 4 wks Groups: NA N at enrollment: 126 N at follow-up: 114 Women, %: 100 Age, mean (range): 39 (21–74) Race/ethnicity: NR Menopausal, n: 44 Parity, mean (range): 2 (0–12) | Inclusion criteria: • Confirmed diagnosis of detrusor instability • Uninhibited detrusor contraction > 15 cm H_2_O on standing provocative urethra cystometry Exclusion criteria: • Urethritis (on urethroscopy) • Cystitis (on cystoscopy) • Neurologic findings on screening test of S2-S4 lower voiding center • MUI • Glaucoma | Uninhibited detrusor contraction starting prior to urethral pressure change, n (%): 73 (64%) Urethral pressure drop (≥ 20 cmH_2_O) prior to detrusor contraction, n (%): 41 (6) | Good response, n (%): 66 (58) Poor response, n (%): 48 (42) Response, women with uninhibited detrusor contraction starting prior to urethral pressure, n (%): Good: 61 (81) Poor: 5 (12) P < 0.01 Response, women with urethral pressure drop (≥ 20 cmH_2_O) prior to detrusor contraction, n (%): Good: 12 (16) Poor: 36 (88) P < 0.01 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: ++ Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Kreder et al., 2002 [See evidence table for Van Kerrebroeck, et al., 2001] Country and setting: Multinational; open label extension × 12 months Enrollment period: NR Funding: NR Author industry relationship disclosures: NR | Design: Prospective case series Open label, uncontrolled, non-randomized extension study of Phase III Intervention: Tolterodine ER 4 mg daily Groups: Tolterodine ER 4 mg daily N at enrollment: 1077 N at follow-up (%): 759 (70.6) Age, mean (range): 60.3 (19.6–93.2) Race/ethnicity: NR Women, N (%): 883 (82) | Inclusion criteria: [See evidence table for Van Kerrebroeck, et al., 2001] Exclusion criteria: [See evidence table for Van Kerrebroeck, et al., 2001] | Frequency ≥ 8 voids/day, n (%): 1041 (96.7) UUI episodes/day ≥ 5, n (%): 1056 (98.1) Voided volume ≤ 200 mL, n (%): 1032 (95.8) Incontinence episodes/week, n (range): 21.6 (0.0–168.0) Voids/day, n (range): 10.9 (2.3–48.6) Voided volume (mL), mean (range): 137.7 (21.1–373.5) Previous treatment for OAB, n (%): 591 (54.9) Previous treatment for OAB with poor efficacy, n (%): 231 (39.1) | Incontinence episodes/week, 3 months, mean change ± SD: −13.4 ± 19.3 P = 0.297 Incontinence episodes/week, 12 months, mean change ± SD: −12.5 ± 19.9 P = 0.5888 Voids/day, 3 months, mean change ± SD: −2.4 ± 3.2 P = 0.0077 Voids/day, 12 months, mean change ± SD: −2.3 ± 3.4 P = 0.0661 Voided volume (mL), 3 months, mean change ± SD: 42.9 ± 55.6 P = 0.6319 Voided volume (mL), 12 months, mean change ± SD: 43.2 ± 60.3 P = 0.6426 Dry mouth, n (%): 139 (12.9) Constipation, n (%): 35 (3.3) Dyspepsia, n (%): 24 (2.2) Upper Respiratory Tract Infection, n (%): 43 (4.0) Bronchitis, n (%): 28 (2.6) UTI, n (%): 44 (4.1) Cystitis, n (%): 23 (2.1) Headache, n (%): 26 (2.4) Back pain, n (%): 35 (3.3) Flu-like illness, n (%): 28 (2.6) Serious adverse events related to tolterodine, n: Urinary retention: 1 Aggravated MS: 1 Med error: 1 Withdrawal due to AEs (N= 107), n (%): Dry Mouth: 19 (1.8) Headache: 9 (0.8) Abd pain: 9 (0.8) Dizziness: 7 (0.7) UTI: 7 (0.7) Dyspepsia: 6 (0.6) Constipation: 6 (0.6) Xerophthalmia: 5 (0.5) Voiding disorder: 5 (0.5) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: + Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Kreder et al., 2003 Country and setting: US and Canada, Community Enrollment period: NR 16 week follow up Funding: Pharmacia Corporation Author industry relationship disclosures: NR | Design: Subgroup analysis of multicenter, single blind cohort Intervention: Tolterodine 1–2 mg b.i.d. Groups: G1: MUI with primary urge G2: UUI N at enrollment: G1: 171 G2: 552 N at follow-up: G1: 170 G2: 551 Women, n (%): G1: 165 (96.5) G2: 464 (84) Age, median (range): G1: 62 (21, 88) G2: 65 (20, 88) Race/ethnicity: NR | Inclusion criteria: • Age ≥ 65 • History, PE, UDS consistent with urge incontinence • ≥ 4 episodes UI on 5 day voiding diary • ≥ 8 voids/day • Either urgency or ≥ 1 UI episodes/day Exclusion criteria: • MUI with predominate stress component • Contraindications to antimuscarinic therapy • Hepatic/renal disease • Symptomatic or recurrent UTI • Hematuria • IC Voiding difficulty with risk of retention Concurrent bladder training Electrostimulation therapy Indwelling catheter CIC Women with reproduction potential Pregnant/nursing Concomitant anticholinergic meds/treatment | Incontinence episodes/day, median (range): G1: 3 (1, 19) G2: 3 (1, 15) ≥ 2 nocturia episodes/day, n (%): G1: 100 (58.5) G2: 334 (60.5) Using pads, n (%): G1: 122 (71) G2: 342 (62) Voided volume (mL), median (range): G1: 169 (62, 506) G2: 164 (31, 524) Duration of symptoms > 5 years, n (%): G1: 91 (53) G2: 259 (47) Previous drug therapy for OAB, n (%): G1: 85 (50) G2: 275 (50) | Incontinence episodes/day, median % change: G1: −67 G2: −75 P = NS Cure rate, achieved dryness, n (%): G1: 66 (39) G2: 243 (44) P = NS Voids/day, median % change: G1: −15 G2: −17 P = NS Cure rate, ≤ 8 voids/day dryness, n (%): G1: 40 (23.5) G2: 130 (24) P = NS Nocturia episodes/day, median % change: G1: −50 G2: −33 P = NS Cure rate, achieving ≤ 2 nocturnal voiding episodes/day, n (%): G1: 83 (83) G2: 254 (76) P = NS Cure rate, achieved no pad usage, n (%): G1: 26 (21) G2: 93 (27) P = NS Voided volume (mL), median change (range): G1: 26.5 (−261, 195) G2: 27 (−345, 389) G1/BL: P < 0.001 G2/BL: P < 0.001 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: − Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Landis et al., 2004 [See evidence table for van Kerrebroeck et al., 2001] Country and setting: Multinational, Community Enrollment period: NR 12 weeks Funding: Pharmacia Author industry relationship disclosures: 2 of 4 ALZA (1) Bristol-Myers Squibb (1) Pharmacia (2) | Design: RCT Intervention: Tolterodine ER vs placebo 1 week run-in period with 12 weeks treatment Groups: G1: Tolterodine ER 4 mg daily G2: placebo Stratified: a: 5–20 UUI episodes/week b: ≥ 21 UUI episodes/week N at enrollment: G1: 492 G1a: 321 G1b: 171 G2: 494 G2a: 284 G2b: 210 N at follow-up: G1a: 321 G1b: 171 G2a: 284 G2b: 210 Women, N (%): G1a: 262 (81.6) G1b: 143 (83.6) G2a: 223 (78.5) G2b: 178 (84.8) Age, mean ± SD: G1a: 60.86 ± 14.45 G1b: 60.04 ± 14.10 G2a: 60.61 ± 13.59 G2b: 61.84 ± 13.85 Race/ethnicity: NR | Inclusion criteria: • Age ≥ 18 • ≥ 5 UUI episodes/week • ≥ 8 voids/day • Symptoms of OAB × 5 months Exclusion criteria: NR | UUI episodes/week, median (range): G1: 16 (5–168) G1a: 11 (5–20) G1b: 34 (21–168) G2: 18 (5–168) G2a: 11 (5–20) G2b: 31.5 (21–168) Voids/day, median (range): G1a: 9.57 (2.57–34.85) G1b: 10.71 (2.28–51.28) G2a: 10.28 (2.28–28.42) G2b: 11.14 (2–37.42) Voided volume (mL), median (range): G1a: 142.72 (36.19–338) G1b: 135.12 (51.45–270.52) G2a: 136.25 (32.51–237.5) G2b: 126.94 (21.16–373.46) Number prior Tx for OAB, n (%): G1a: 162 (50.6) G1b: 100 (58.5) G2a: 139 (49.1) G2b: 117 (55.7) Number prior Tx for OAB w/good efficacy, n (%): G1a: 85 (52.8) G1b: 63 (63.0) G2a: 84 (60.4) G2b: 68 (58.6) | UUI episodes/week, median change: G1: −9.0 G1a: −6.0 G1b: −21 G2: −5.0 G2a: −4.0 G2b: −9.5 G1/G2: P < 0.0001 G1a/G2a: P < 0.0001 G1b/G2b: P < 0.0001 UUI episodes/week, median % change: G1a: −71.42 G1b: −67.56 G2a: −38.46 G2b: −29.81 G1a/G2a: P = 0.0264 (adjusted) G1b/G2b: P = 0.0221 (adjusted) Voids/day, median change: G1a: −1.22 G1b: −1.9 G2a: −0.85 G2b: −0.4 G1a/G2a: P < 0.04 G1b/G2b: P < 0.02 Voided volume (mL), median change: G1a: 24.0 G1b: 27.0 G2a: 4.0 G2b: 2.9 G1a/G2a: P < 0.0001 G1a/G2a: P < 0.0001 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: − Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Lauti et al., 2008 Country and setting: New Zealand, Academic Enrollment period: February 2003 to July 2003 Funding: University of Otago Author industry relationship disclosures: None | Design: RCT pilot study, unmasked Intervention: Oxybutynin vs. bladder retraining vs. combination therapy Groups: G1: Oxybutynin 2.5 mg/day (daily dose could be increased by 2.5 mg every 5 days to a maximum of 15 mg/day) G2: Bladder retraining G3: Combination therapy N screened: 120 N at enrollment: G1: 21 G2: 16 G3: 19 N at 3 month follow-up: G1: 18 G2: 16 G3: 12 N at 12 month follow-up: G1: 16 G2: 14 G3: 12 Age, mean ± SD: G1: 53.8 ± 14.8 G2: 63.9 ± 17.2 G3: 47.6 ± 16.3 Race/ethnicity: NR Women, %: Total: 100 Parrous, %: G1: 81 G2: 62.5 G3: 73.7 | Inclusion criteria: • Age > 18 • Predominant UUI Exclusion criteria: • Predominant SUI • Contraindications to anticholinergic drugs • Current UTI • Neurological disease • Psychiatric disorder • Untreated co-existing pelvic organ prolapse below the hymenal ring • Obstructed voiding • Functional-reversible cause of incontinence • Inability to toilet independently • Limited fluency of written/spoken English • Current or recent use of any of the trial interventions | Urgency episodes/day, mean ± SD: G1: 3.8 ± 2.7 G2: 3.1 ± 2.2 G3: 3.5 ± 2.0 Incontinence episodes/day, mean ± SD: G1: 2.2 ± 1.5 G2: 1.0 ± 1.1 G3: 1.8 ± 1.6 Nocturia episodes/day, mean ± SD: G1: 1.1 ± 1.0 G2: 1.4 ± 1.0 G3: 0.8 ± 0.7 Voids per day, mean ± SD: G1: 7.8 ± 2.8 G2: 8.0 ± 1.7 G3: 8.4 ± 2.5 OAB-q total HRQL, mean ± SD: G1: 73.1 ± 17.4 G2: 69.5 ± 24.6 G3: 71.6 ± 21.5 OAB-q severity, mean ± SD: G1: 47.0 ± 16.2 G2: 42.3 ± 17.7 G3: 45.9 ± 18.7 OAB-q coping, mean ± SD: G1: 72.0 ± 21.6 G2: 66.2 ± 31.7 G3: 73.8 ± 26.2 OAB-q concern, mean ± SD: G1: 68.2 ± 19.0 G2: 68.8 ± 27.6 G3: 63.8 ± 29.2 OAB-q sleep, mean ± SD: G1: 63.1 ± 28.7 G2: 59.8 ± 29.9 G3: 55.1 ± 27.6 OAB-q social, mean ± SD: G1: 92.5 ± 14.6 G2: 85.4 ± 19.9 G3: 92.8 ± 18.6 SF-12 quality of life, physical, mean ± SD: G1: 49.0 ± 9.6 G2: 41.7 ± 11.5 G3: 46.2 ± 10.6 SF-12 quality of life, mental, mean ± SD: G1: 49.1 ± 9.3 G2: 53.1 ± 8.8 G3: 46.3 ± 8.3 | Urgency episodes/day, 3 mos, mean ± SD: G1: 2.2 ± 1.8 G2: 1.5 ± 2.1 G3: 1.7 ± 1.8 Urgency episodes/day, 12 mos, mean ± SD: G1: 2.3 ± 2.5 G2: 1.9 ± 2.1 G3: 2.0 ± 1.1 Incontinence episodes/day, 3 mos, mean ± SD: G1: 0.8 ± 0.8 G2: 0.1 ± 0.3 G3: 0.6 ± 0.8 Incontinence episodes/day, 12 mos, mean ± SD: G1: 0.9 ± 0.0 G2: 0.9 ± 1.0 G3: 0.8 ± 0.7 Nocturia episodes/day, 3 mos, mean ± SD: G1: 1.0 ± 0.5 G2: 0.8 ± 0.7 G3: 0.6 ± 0.5 Nocturia episodes/day, 12 mos, mean ± SD: G1: 1.0 ± 0.9 G2: 1.2 ± 0.6 G3: 0.7 ± 0.7 Voids/day, 3 mos, mean ± SD: G1: 6.7 ± 1.8 G2: 6.3 ± 1.6 G3: 6.7 ± 2.2 Voids/day, 12 mos, mean ± SD: G1: 7.2 ± 1.1 G2: 6.8 ± 1.4 G3: 7.6 ± 1.5 OAB-q total HRQL, 3 mos, mean ± SD: G1: 82.3 ± 16.1 G2: 89.6 ± 9.4 G3: 91.8 ± 7.4 OAB-q total HRQL, 12 mos, mean ± SD: G1: 87.9 ± 11.6 G2: 81.6 ± 19.3 G3: 88.9 ± 9.9 OAB-q severity, 3 mos, mean ± SD: G1: 37.2 ± 22.0 G2: 16.8 ± 12.0 G3: 21.6 ± 10.9 OAB-q severity, 12 mos, mean ± SD: G1: 24.6 ± 10.6 G2: 33.1 ± 16.6 G3: 21.9 ± 14.8 OAB-q coping, 3 mos, mean ± SD: G1: 79.2 ± 22.1 G2: 91.6 ± 9.5 G3: 92.7 ± 9.4 OAB-q coping, 12 mos, mean ± SD: G1: 89.2 ± 13.7 G2: 81.5 ± 23.7 G3: 90.5 ± 10.0 OAB-q concern, 3 mos, mean ± SD: G1: 78.6 ± 18.0 G2: 87.7 ± 14.5 G3: 90.2 ± 12.4 OAB-q concern, 12 mos, mean ± SD: G1: 85.3 ± 15.5 G2: 81.7 ± 19.7 G3: 85.2 ± 13.4 OAB-q sleep, 3 mos mean ± SD: G1: 77.7 ± 24.9 G2: 81.3 ± 14.6 G3: 85.0 ± 19.6 OAB-q sleep, 12 mos, mean ± SD: G1: 79.9 ± 18.3 G2: 72.0 ± 24.5 G3: 83.2 ± 18.4 OAB-q social, 3 mos, mean ± SD: G1: 96.4 ± 9.7 G2: 95.6 ± 7.0 G3: 98.9 ± 1.9 OAB-q social, 12 mos, mean ± SD: G1: 97.3 ± 7.1 G2: 91.9 ± 14.2 G3: 97.3 ± 6.9 SF-12 quality of life, physical G1: 50.6 ± 8.0 G2: 42.1 ± 12.7 G3: 48.4 ± 10.8 SF-12 quality of life, physical, 12 mos, mean ± SD: G1: 50.0 ± 7.3 G2: 45.1 ± 13.9 G3: 45.3 ± 13.4 SF-12 quality of life, mental, 3 mos, mean ± SD: G1: 50.4 ± 9.6 G2: 51.2 ± 9.5 G3: 46.7 ± 7.6 SF-12 quality of life, mental, 12 mos, mean ± SD: G1: 49.6 ± 7.5 G2: 50.1 ± 10.7 G3: 50.6 ± 8.4 Dry mouth, n (%): G1: 3 (21) G2: 5 (46) G3: 5 (42) Headaches, n (%): G1: 6 (43) G2: 1 (11) G3: 7 (58) Dizziness, n (%): G1: 4 (29) G2: 2 (20) G3: 3 (25) Constipation, n (%): G1: 3 (21) G2: 3 (27) G3: 3 (27) Fatigue, n (%): G1: 9 (64) G2: 5 (46) G3: 7 (64) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Method and blinding: − Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: + Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Layton et al., 2001 Country and setting: England, Community Enrollment period: November 1998 to May 1999 Funding: Pharmacia Upjohn Author industry relationship disclosures: NR | Design: Prospective observational cohort Intervention: Tolterodine prescription event monitoring in UK Groups: NA N at enrollment: 35,295 had commenced treatment 26,991 green forms mailed out 14,526 returned forms Response rate: 53.8% Age, mean ± SD: 62.7 ± 16.4 Women, N (%): 9965 (68.6) Parity: NR | Inclusion criteria: • Patients prescribed tolterodine in general practice in UK Exclusion criteria: • None | | Dry mouth, n: 250 Unspecified adverse effects, n: 168 Headache, n: 123 Constipation, n: 78 General malaise, n: 78 Hallucinations, n: 23 Palpitations/tachycardia, n: 42 Other cardiac arrhythmias, n: 29 Chest pains, n: 87 | Quality: Overall quality score: good INTERNAL VALIDITY: good Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: NA Drop-out rates: NA Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: NR Baseline characteristics: + Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: −
Author: Lee et al., 2002 Country and setting: South Korea, University Enrollment period: NR Funding: Pharmacia Corp Author industry relationship disclosures: NR | Design: RCT Intervention: Tolterodine 2mg b.i.d. vs Oxybutynin 5mg b.i.d. Groups: G1: Tolterodine 2mg b.i.d. G2: Oxybutynin 5mg b.i.d. N at enrollment: G1: 112 G2: 116 N at follow-up: G1: 97 G2: 90 Women, n (%): G1: 84 (74) G2: 92 (79) Age, mean (range): G1: 52 (27, 82) G2: 52 (20, 86) Race/ethnicity (%): Asian: G1: 100 G2: 100 BMI, kg/m^2^ (range): G1: 23 (17, 32.5) G2: 23.5 (16, 38) Previous drug therapy: N (%) G1: 36 (32) G2: 26 (22) | Inclusion criteria: • Age ≥ 18 • OAB symptoms > 6 mos • ≥ 8 voids/day, with or without incontinence (measured by diary) Exclusion criteria: • SUI • Women not using reliable contraception • Pregnant or nursing • Prior treatment with anticholinergic < 2 wks • Renal or hepatic disease • Narrow angle glaucoma • Urinary retention • Gastric retention • Hypersensitivity to drugs • UTI • IC • Hematuria • BOO • Concomitant bladder training, e-stim treatment • Indwelling catheter • CIC • Concomitant treatment for OAB ≤ 2 mos | Incontinence episodes/day, mean (range): G1: 2.6 (0.3, 9.3) G2: 2.4 (3.0, 14.7) Patients with incontinence episodes, n (%): G1: 46 (41) G2: 42 (36) Voids/day, mean (range): G1: 12.2 (8.0, 23.7) G2: 12.4 (7.7, 29.7) | Incontinence episodes/day, mean change ± SD (% change): G1: −2.2 ± 2.3 (−85) G2: −1.4 ± 1.8 (−58) G1/BL: P = 0.0001 G1/BL: P = 0.0001 G1/G2: P = 0.10 Voids/day, mean change ± SD (% change): G1: −2.6 ± 2.9 (−21) G2: −1.8 ± 4.2 (−15) G1/BL: P = 0.0001 G1/BL: P = 0.0001 G1/G2: P = 0.14 Benefit of Tx, %: G1: 45 G2: 46 G1/G2: P = NS Patients reporting adverse events, n (%): G1: 62 (55) G2: 94 (82) Discontinued due to AEs, n (%): G1: 11 G2: 18 Dry mouth, n (%): G1: 39 (35) G2: 72 (63) G1/G2: P = 0.001 Dry mouth, mild, n (%): G1: 29 (26) G2: 40 (35) Dry mouth, moderate, n (%): G1: 9 (8) G2: 26 (23) Dry mouth, severe, n (%): G1: 1 (1) G2: 6 (5) Voiding disorder, n (%): G1: 10 (9) G2: 16 (14) Dyspepsia, n (%): G1: 8 (7) G2: 6 (5) Abdominal pain, n (%): G1: 6 (5) G2: 6 (5) Headache, n (%): G1: 4 (4) G2: 6 (5) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Leung et al., 2002 Country and setting: Hong Kong, Academic, uro-gynecology centers Enrollment period: April 2000 to December 2000 Funding: Pharmacia Limited Author industry relationship disclosures: NR | Design: RCT Intervention: oral tolterodine 2 mg vs. oxybutynin 5 mg b.i.d. for 10 weeks Groups: G1: tolterodine 2 mg G2: oxybutynin 5 mg b.i.d. N at enrollment: G1: 53 G2: 53 N at follow-up: G1: 44 G2: 45 Women, %: 100 Age, median (IQR): G1: 51 (44, 67) G2: 49 (43, 57) Race/ethnicity, %: Hong Kong Chinese: 100 Menopausal, %: G1: 66.0 G2: 45.3 G1/G2: P = 0.073 | Inclusion criteria: • UDS-confirmed detrusor instability • Age ≥ 18 • Diagnosis of OAB (phasic detrusor contraction with an amplitude ≥ 15 cmH_2_O by ICS criteria • ≥ 8 voids/day • ≥ 1 incontinent episodes/day Exclusion criteria: • Genuine SUI • Voiding difficulty (max flow rate < 10mL/s with a residual volume of > 200mL) • Recurrent or acute UTIs • Intermittent or indwelling catheter • Hematuria or bladder cancer • Currently on treatment for OAB or on anticholinergic medications • Psychiatric disease or cognitive impairment (by history or MMSE) • Cardiac, hepatic, renal, or hematologic disorder • Contraindications for antimuscarinic agents • Pregnant or lactating • Women not using reliable contraception | Overall severity, VAS score, wk 0, median (IQR): G1: 5.2 (5.0,7.85) G2: 5.7 (5.0, 8.0) Peak flow rate (mL/s), median (IQR) G1: 13.1 (10.0, 17.4) G2: 13.9 (11.2, 21.2) Max cystometric capacity (mL), median (IQR): G1: 333 (263.3, 400.8) G2: 373 (293, 416.8) | Overall severity, VAS score, wk 4, median (IQR): G1: 5.0 (5.0, 7.0) G2: 5.0 (3.0, 6.0) Overall severity, VAS score, wk 10, median (IQR): G1: 5.0 (3.5, 6.0) G2: 5.0 (4.0, 6.0) P < 0.005 for change with duration of treatment, P < 0.005 for linear pattern Perceived change in symptoms, double-sided VAS score, wk 4, median (IQR): G1: 1.0 (0.0, 2.5) G2: 2.0 (0.0, 3.0) Perceived change in symptoms, double-sided VAS score, wk 10, median (IQR): G1: 1.0 (0.0, 2.0) G2: 2.0 (0.0, 3.0) G1/G2: P = 0.053 ITT analysis G1/G2: P = 0.047 per-protocol analysis Urinary pad weight (g), ITT analysis, median change (IQR): G1: −5.0 (−54.75, 0) G2: 0.0 (−4.5, −0.75) G1/G2: P = 0.019 Urinary pad weight (g), per-protocol analysis, median change (IQR): G1: −5.0 (−54.75, 0) G2: 0.0 (−5.0, 0) G1/G2: P = 0.031 Drug compliance, %: G1: 75 G2: 87.5 Significance of variables, change with duration of treatment, ITT analysis: XQ overall dryness: P < 0.001 XQ uncomfortable: P < 0.001 XQ sleep: P = 0.020 XQ speak: P = 0.042 XQ swallow: P = 0.002 XQ liquid: P = 0.005 XQ dentures: P = 0.361 Diary frequency: P < 0.001 Diary urgency episodes: P = 0.109 Diary incontinence episodes: P = 0.203 Diary pad use: P = 0.593 Significance of variables, between groups, ITT analysis: XQ overall dryness: P = 0.062 XQ uncomfortable: P = 0.285 XQ sleep: P = 0.626 XQ speak: P = 0.652 XQ swallow: P = 0.197 XQ liquid: P = 0.451 XQ dentures: P = 0.480 Diary frequency: P = 0.965 Diary urgency episodes: P = 0.672 Diary incontinence episodes: P = 0.993 Diary pad use: P = 0.665 Drug compliance rate (IQR): G1: 75.0 (8.9, 98.8) G2: 87.5 (11.4, 99.3) Withdrawal rate, %: G1: 17.0 G2: 15.1 Side effects, %: G1: 60.4 G2: 49.1 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: − Power calculation: − Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Lose et al., 2000 Country and setting: Denmark, 26 clinics in the Dept of Obstetrics & Gynaecology Outpatient Clinic Enrollment period: September 1994 to April 1996 Funding: NR Author industry relationship disclosures: NR | Design: RCT parallel group with active control, sequential numbers Intervention: oestradiol-releasing vaginal ring vs. oestriol vaginal pessaries (DANUGA study) Groups: G1: 7.5 mg oestradiol per 24 h oestradiol-releasing vaginal ring × 12 wks G2: 1–0.5 mg oestriol vaginal pessaries per day × 3 wks followed by 1 every 2 days for 21 wks N at enrollment: G1: 134 G2: 117 N at follow-up: G1: 129 G2: 114 Age, yrs ± SD: G1: 65.6±9.5 G2: 66.8 ± 9.1 Race/ethnicity: NR Women, N (%): G1: 134 (100) G2: 117 (100) Height (cm) mean ± SD: G1: 164 ± 5.9 G2: 164 ± 6.4 Body weight (kg) mean ± SD: G1: 69.8 ± 12.7 G2: 68.1 ± 12.4 | Inclusion criteria: • Women who reported at least one bothersome lower urinary tract symptom appearing at least two years after spontaneous or surgical postmenopause Exclusion criteria: • known or suspected oestrogen-dependent neoplasia or mammary, ovarian endometrioid) or corpus uteri malignancies • vaginal bleeding of unknown origin • clinically significant liver disease • acute or intermittent porphyria, uterovaginal prolapse of grade II or III • sex hormone treatment within the last 6 mos • previous participation in clinical trials within 3 mos prior to inclusion • signs of vaginal irritation other than atrophy derived or signs of vaginal ulceration | Persistence of symptoms (months), mean ± SD: G1: 74 ± 88 G2: 80 ± 101 Urgency %: G1: 84 G2: 91 Frequency %: G1: 75 G2: 73 Urge Incontinence %: G1: 66 G2: 64 Stress Incontinence %: G1: 67 G2: 58 Nocturia %: G1: 60 G2: 66 Dysuria %: G1: 25 G2: 23 Mucusal atrophy, n (%): G1: 127 (95) G2: 115 (98) Vaginal pH, mean: G1: 6.0 G2: 6.0 Urinary symptoms measured by VAS, mean: G1: 21.1 G2: 23.2 Concimitant medication n (%): G1: 54 (41) G2: 50 (42) | Responder rate, 24 weeks, %: Urgency : G1: 51 G2: 56 Frequency : G1: 61 G2: 58 UUI: G1: 58 G2: 58 SUI: G1: 53 G2: 59 Nocturia: G1: 51 G2: 54 Dysuria: G1: 76 G2: 63 G1/G2: P = 0.282 Vaginal dryness: G1: 77 G2: 89 Dyspareunia: G1: 75 G2: 78 Symptom free rate, 24 weeks, %: Urgency: G1: 27 G2: 33 Frequency: G1: 34 G2: 44 G1/G2: P = 0.203 UUI: G1: 33 G2: 34 SUI: G1: 34 G2: 41 Nocturia: G1: 31 G2: 35 Dysuria: G1: 67 G2: 52 G1/G2: P = 0.244 Vaginal dryness: G1: 57 G2: 83 G1/G2: P = 0.019 Dyspareunia : G1: 61 G2: 71 Vaginal pH at 24 weeks, mean: G1: 4.8 G2: 4.8 Subjective judgement of administration form, %: Excellent: G1: 60 G2: 14 Good: G1: 27 G2: 34 Acceptable: G1: 6 G2: 48 Bad: G1: 2 G2: 3 Unacceptable: G1: 3 G2: 2 P = 0.0001 At least 1 adverse events, n (%): 49 (19.5) difference between groups = NS Vaginal discomfort, n: G1: 6 G2: 13 Leukorrhea, n: G1: 7 G2: 7 Vaginal itching, n: G1: 1 G2: 4 Breast pain, n: G1: 2 G2: 3 Vaginal haemorrhage, n: G1: 2 G2: 2 Weight increase, n: G1: 2 G2: 3 Breast discharge, n: G1: 1 G2: 3 Abdominal pain, n: G1: 2 G2: 0 Nausea, n: G1: 2 G2: 0 Headache, n: G1: 1 G2: 1 Pruritus, n: G1: 1 G2: 1 Flushing, n: G1: 1 G2: 0 Urinary urgency, n: G1: 1 G2: 0 Change in body smell, n: G1: 0 G2: 1 Malaise, n: G1: 0 G2: 1 Hypertrichosis, n: G1: 0 G2: 1Stranguria, n: G1: 1 G2: 0 Oedema, n: G1: 1 G2: 0 Palpitation, n: G1: 1 G2: 0 Increased sweating, n: G1: 1 G2: 0 Uterine discomfort, n: G1: 0 G2: 1 Amnesia, n: G1: 0 G2: 1 Pelvic inflammation, n: G1: 1 G2: 0 | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: + Masking: − Pt selection criteria: + Loss to followup: ++ Drop-out rates: + Power calculation: + Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: − Intervention description: +
Author: Macaulay et al., 1987 Country and setting: UK, Specialty treatment center Enrollment period: NR Funding: Wellcome Trust, trustees of St. George’s Hospital Author industry relationship disclosures: NR | Design: RCT (randomization not specified) Intervention: Brief eclectic psychotherapy, bladder training or medication Groups: G1: psychotherapy G2: bladder drill G3: Propan-theline N at enrollment: G1: 19 G2: 16 G3: 15 N at follow-up: G1: 18 G2: 15 G3: 14 Women, %: 100 Age: NR Race/ethnicity: NR Follow-up: 3 months | Inclusion criteria: • Previous completion of survey on psych conditions w/OAB • Detrusor instability on UDS or sensory urgency Exclusion criteria: NR | Detrusor instability, n: G1: 10 G2: 8 G3: 8 Sensory urgency, n: G1: 9 G2: 8 G3: 7 Voids/day, mean: G1: NR G2: NR G3: 10.8 Bladder capacity (mL), mean: G1: 393 G2: NR G3: 323 Bladder volume (mL), first sensation, mean: G1: 107 G2: 110 G3: 70 Detrusor pressure rise (cm H_2_O), mean: G1: NR G2: 45.5 G3: NR | Voids/day, mean: G1: NR G2: NR G3: 8.3 G3/BL: P < 0.005 Bladder capacity (mL), mean: G1: 414 G2: NR G3: 368 G1/BL: P = NS G3/BL: P = NS Bladder volume (mL), first sensation, mean: G1: 142 G2: 150 G3: 137 G1/BL: P = NS G2/BL: P < 0.05 G3/BL: P = 0.06 Detrusor pressure rise (cm H_2_O), mean: G1: NR G2: 29.5 G3: NR G2/BL: P < 0.05 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: − Masking: − Pt selection criteria: − Loss to followup: ++ Drop-out rates: ++ Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: −, NR Baseline OAB status: NR Baseline characteristics: − Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Malone-Lee et al., 2003 Country and setting: UK, Hospital Enrollment period: 1993–1999 Funding: NR Author industry relationship disclosures: NR | Design: Prospective observational Intervention: Oxybutynin 2.5mg b.i.d. and bladder retraining Groups: G1: urinary frequency and urgency w/detrusor instability G2: urinary frequency and urgency w/o detrusor instability N at enrollment: G1: 266 G2: 86 N at follow-up: Total: 347 G1: NR G2: NR Age, mean (range): G1: 54.8 (20, 90) G2: 51.8 (21, 88) Race/ethnicity: NR | Inclusion criteria: • Women • Age ≥ 18 • ≥ 8 voids/day Exclusion criteria: • Neurological disease • Significant stress incontinence • Symptomatic UTI • Interstitial cystitis | Incontinence episodes/day, median (95% CI): G1: 2 (0, 7) G2: 2 (0, 6.3) Voids/day median (95% CI): G1: 14 (8, 24) G2: 12 (8, 22) | Incontinence episodes/day, median change (95% CI): G1: 0 (2, 6) G2: 0 (2, 6) G1/G2: P = 0.73 Voids/day, median change (95% CI): G1: −5 (1.9–14) G2: −5 (1–12.3) G1/G2: P = 0.61 Dry mouth, n (%): G1: 219 (84) G2: 69 (70) Constipation, n (%): G1: 84 (32) G2: 19 (22) Heartburn, n (%): G1: 71 (27) G2: 20 (23) Dry skin, n (%): G1: 46 (18) G2: 4 (5) G1/G2: P = 0.01 Headache, n (%): G1: 25 (10) G2: 3 (3.5) Dry eyes, n (%): G1: 12 (5) G2: 1 (1) | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: ++ Drop-out rates: NR Power calculation: − Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: + Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Mattiason et al., 2003 Country and setting: Sweden, Denmark, Norway (Tolterodine Scandinavian Study Group) Enrollment period: October 1999 to December 2000 Funding: Pharmacia Corp Author industry relationship disclosures: NR | Design: RCT, single-blinded (balanced blocks of 4, computerized randomization list) Intervention: Pharmacologic ± behavioral therapy; Tolterodine 2mg b.i.d. ± bladder training (BT); Tolterodine dosage could be decreased to 1mg po b.i.d. during the first 2 wks if intolerable SE; BT taught with a written handout Groups: G1: Tolterodine + BT x 24 wks G2: Tolterodine x 24 wks N at enrollment: Total: 505 N at follow-up: G1: 244 G2: 257 N Completed treatment: G1: 77% G2: 79% Total: 74% Women, n (%) G1: 177 (73) G2: 201 (78) Age, median (range): G1: 62 (19, 86) G2: 63 (22, 86) Race/ethnicity: NR Follow-up: 24 weeks | Inclusion criteria: • Age ≥ 18 • ≥ 8 voids/day and urinary urgency (± UUI) as determined by 1 wk bladder diary • With or without UUI • Women of reproductive age had to be using reliable birth control Exclusion criteria: • Contraindication to antimuscarinic therapy • Use of electrostimulation therapy or BT within prior 3 mo • Indwelling catheter or intermittent catheterization • Pregnancy or lactation Use of anticholinergic agents or concomitant treatment for OAB (estrogen permitted) | Urgency episodes/day, mean (range): G1: 6.0 (0, 23.0) G2: 6.6 (0, 34.3) Incontinence episodes/day, mean (range): G1: 2 (0.3, 20.3) G2: 2.3 (0.3, 16.3) Voids/day, mean (range): G1: 10.3 (7.3, 27.6) G2: 10.6 (7.7, 24.6) Duration of symptoms > 5 years, n (%): G1: 120 (49) G2: 124 (48) Previous drug therapy for OAB, n (%): G1: 40 (160 G2: 35 (14) Previous surgery affecting lower urinary tract, n (%): G1: 28 (11.5) G2: 30 (12) Symptoms caused at least moderate problems, %: G1: 92 G2: 93 | Urgency episodes/day, median % change (IQR): G1: −38 (−76.7, −14.1) G2: −38 (−68.7, −8.0) G1/G2: P = 0.75 Incontinence episodes/day, median IQR% change; n=301: G1: −87 (−100, −20) G2: −81 (−100, −41.8) G1/G2: P = 0.28 Voids/day, median % change (IQR): G1: −33 (−42.3, 21.3) G2: −25 (−38.8, −13.0) G1/G2: P < 0.001 Voided volume (mL), median % change (IQR): G1: 31.5 (13.3, 56.2) G2: 20 (3.1, 45.4) G1/G2: P < 0.001 Symptoms are “minor or less”, %: G1: 66.5 G2: 61.5 Overall improvement in symptoms, %: G1: 76 G2: 71 Worsening of symptoms, %: G1: 3 G2: 5 Dry mouth, n (%): G1: 76 (31) G2: 90 (35) Headache, n (%): G1: 15 (6) G2: 21 (8)Constipation, n (%): G1: 7 (3) G2: 14 (5) ≥ 1 SE, n (%): G1: 158 (65) G2: 177 (69) G1/G2: P = NS Withdrawal due to, %: AE: 15 Withdrawal due to lack of efficacy: 3 Withdrawal of consent : 2 Protocol violations: 1 Completed treatment: G1: 77% G2: 79% | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Messelink, 1999 Country and setting: NR Enrollment period: NR Funding: Pharmacia & Upjohn Author industry relationship disclosures: NR | Design: Compilation of findings from four Phase II and eight Phase III studies with open label follow-up; not all trials have been previously published* Intervention: Tolterodine 2mg b.i.d. Groups: G1: tolterodine 2mg b.i.d. previously in 4 week placebo controlled trial; continued for 12 months open label G2: tolterodine 2mg b.i.d. previously in 12 week placebo controlled trial continued for 9 months open label N at enrollment: G1: 135 G2: 121 N at follow-up: G1: 135 G2: 121 Age, yrs (range): G1: 60 (18, 92) G2: 61 (18, 88) Race/ethnicity: NR Women, %: G1: 68 G2: 76 Parity: NR | Inclusion criteria: •Participants in prior trials (details NR) •Proceeded into long term open label study Exclusion criteria: •NR | Incontinence episodes/day, mean: G1: 2.9 G2: 3.5 Voids/day, mean: G1: 10.9 G2: 11.4 Voided volume (mL), mean: G1: 159 G2: 159 | Incontinence episodes/day, 3 months, mean: G1: ND G2: 1.4 Incontinence episodes/day, 6 months, mean: G1: 1.4 G2: ND Incontinence episodes/day, 9 months, mean: G1: ND G2: 1.5 Incontinence episodes/day, 12 months, mean: G1: 1.6 G2: ND Voids/day, 3 months, mean: G1: ND G2: 8.8 Voids/day, 6 months, mean: G1: 8.6 G2: ND Voids/day, 9 months, mean: G1: ND G2: 8.9 Voids/day, 12 months, mean: G1: 8.6 G2: ND Voided volume (mL), 3 months, mean: G1: ND G2: 201 Voided volume, (mL), 6 months, mean: G1: 193 G2: ND Voided volume (mL), 9 months, mean: G1: ND G2: 199 Voided volume (mL), 12 months, mean: G1: 190 G2: ND | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: − Pt selection criteria: + Loss to followup: NR Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: + Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Michel et al., 2002 Country and setting: Germany, Community Enrollment period: NR 12 week follow up Funding: Pharmacia GmbH Author industry relationship disclosures: 1 of 4 Pharmacia(1) Sanofi- Synthelabo(1) | Design: Open-label observational post-marketing surveillance Intervention: Tolterodine Groups: Tolterodine Median dose: 2 mg daily Dose (mg), mean ± SD: 3.81 ± 1.16 N at enrollment: 2,250 N at follow-up: 1,979 Women, n (%): 1,730 (76.9) Age, mean ± SD: 61.1 ± 13.8 Race/ethnicity: NR BMI, kg/m^2^ ± SD: 73.2 ± 11.3 | Inclusion criteria: •Physician medical judgement Exclusion criteria: NR | Urgency episodes/day, mean ± SD: 8.4 ± 5.1 Incontinence episodes/day, mean ± SD: 3.4 ± 4.2 Voids/day, mean ± SD: 12.4 ± 4.3 | Urgency episodes/day, mean ± SD: 2.0 ± 3.0 P = NR Incontinence episodes/day, mean ± SD: 0.8 ± 2.0 P = NR Voids/day, mean ± SD: 7.7 ± 2.7 P = NR Urgency, successful treatment, OR (95% CI): Gender, M/F: 0.764 (0.583, 1.001) P = 0.0508 Age, years: 0.981 (0.973, 0.990) P < 0.001 Frequency, BL episodes/day: 1.038 (0.997– 1.080) P = 0.0724 Urgency, BL episodes/day: 0.851 (0.823, 0.880) P < 0.001 Incontinence, BL episodes/day: 0.979 (0.950, 1.000) P = 0.1735 Tolterodine dose, mg/day: 0.913 (0.830, 1.005) P = 0.0623 Incontinence, successful treatment, OR (95% CI): Gender, M/F: 1.453 (1.062, 1.990) P = 0.0196 Age, years: 0.978 (0.968, 0.987) P < 0.001 Frequency, BL episodes/day: 1.034 (0.993, 1.076) P = 0.1036 Urgency, BL episodes/day: 1.053 (1.018, 1.088) P = 0.0027 Incontinence, BL baseline episodes/day: 0.744 (0.716, 0.774) P < 0.001 Tolterodine dose, mg/day: 0.866 (0.784, 0.956) P = 0.0043 Frequency, successful treatment, OR (95% CI): Gender, M/F: 0.745 (0.552, 1.004) P = 0.0532 Age, years: 0.981 (0.971, 0.991) P = 0.001 Frequency, BL episodes/day: 0.735 (0.701, 0.771) P < 0.001 Urgency, BL episodes/day: 1.008 (0.975, 1.041) P = 0.6526 Incontinence, BL episodes/day: 0.969 (0.937, 1.002) P = 0.0644 Tolterodine dose, mg/day: 1.070 (0.957, 1.196) P = 0.2335 Effect on Global efficacy, OR (95% CI): Gender, M/F: 0.656 (0.526, 0.818) P = 0.0002 Age, years: 0.986 (0.980, 0.993) P < 0.001 Frequency, BL epsidoes/day:1.002 (0.972, 1.033) P = 0.8896 Urgency, BL episodes/day: 1.009 (0.984, 1.033) P = 0.4906 Incontinence, BL episodes/day: 0.963 (0.939, 0.987) P < 0.0026Tolterodine dose, mg/day: 1.000 (0.926, 1.080) P = 0.9971 Effect on global tolerability of Tolterodine, OR (95% CI): Gender, M/F: 0.993 (0.790, 1.249) P = 0.9519 Age, years: 0.995 (0.988, 1.002) P = 0.1915 Frequency, BL episodes/day: 1.002 (0.971, 1.034) P = 0.8995 Urgency, BL episodes/day: 1.022 (0.997, 1.048) P = 0.08 Incontinence, BL episodes/day: 0.990 (0.965, 1.016) P < 0.459 Tolterodine dose, mg/day: 1.114 (1.028, 1.206) P = 0.008589 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: − Loss to followup: + Drop-out rates: − Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Michel et al., 2007* Michel et al., 2005 Country and setting: Germany, NR Enrollment period: November 2001 to June 2003 Funding: Pharmacia (became Pfizer before publication) Author industry relationship disclosures: 5 of 5* 4SC (1) Astellas (1) Boehringer Ingelheim (2) Eli Lilly (2) Pfizer (4) Theravance (1) Anformed (1) | Design: Retrospective cohort, open label Intervention: Tolterodine ER Groups: G1: Incontinent G2: Continent N at enrollment: Total: 3,824 G1: 2,571 G2: 1,253 N at follow-up: Total: 3,416 Women, %: Total: 75.8 G1: 81.7 G2: 62.6 P < 0.001 Age, mean ± SD: Total: 64.8 ± 13.3 G1: 66.3 ± 12.6 G2: 61.4 ± 14.1 P < 0.001 Race/ethnicity: NR Follow-up: 9 months | Inclusion criteria: NR Exclusion criteria: NR | Urgency episodes/day, mean ± SD: Total: 7.9 ± 5.2 G1: 8.0 ± 5.2 G2: 7.7 ± 5.2 P = 0.1937 Incontinence episodes/day, mean ± SD: G1: 4.8 ± 3.7 G2: NA Voids/day, mean ± SD: Total: 14.0 ± 4.6 G1: 14.1 ± 4.6 G2: 13.5 ± 4.4 P < 0.001 Daytime voids/day, mean ± SD: Total: 10.7 ± 3.7 G1: 10.8 ± 3.7 G2: 10.4 ± 3.4 P = 0.0128 Frequency ≥ 8 voids/day, %: G1: 95.7 G2: 95.2 Nocturia episodes/day, mean ± SD: Total: 3.4 ± 1.7 G1: 3.5 ± 1.8 G2: 3.2 ± 1.6 P < 0.001 Pad use/day, mean ± SD: G1: 3.4 ± 2.8 G2: 0.1 ± 0.6 P < 0.001 Duration of symptoms (mos), mean ± SD: G1: 50 ± 53 G2: 40 ± 46 P < 0.001 Previous treatment, %: G1: 50.8 G2: 44.8 P = 0.0007 | Incontinence episodes/day, mean change ± SD: G1: −3.8 ± 3.5 G2: NA Urgency episodes/day, mean ± SD: Total: 1.6 ± 2.8 No urgency, %: G1: 53.4 G2: 63.2 Voids/day, mean ± SD: Total: 7.5 ± 3.0 Daytime voids/day, mean ± SD: Total: 6.2 ± 2.3 Frequency ≥ 8 voids/day, %: G1: 43.7 G2: 39.1 Nocturia episodes/day, mean ± SD: Total: 1.4 ± 1.1 Pad use/day, mean change ± SD: G1: −2.4 ± 2.5 Limitation of daily activities, score change ± SD: G1: 4.49 ± 2.65 G2: 4.10 ± 2.51 Limitations in daily life caused by bladder problems, score ± SD: G1: 7.59 ± 1.65 G2: 6.66 ± 1.69 P < 0.001 Total adverse events, n (%): Total: 496 (13.0) Dry mouth, n (%): 299 (7.8) Withdrew: 11% Unable to tolerate medication: 2.8% Administrative reasons: 2.6% Lack of efficacy: 2.4% Patient request: 1.2% | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: − Loss to followup: NR Drop-out rates: NA Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: + Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Michel et al,, 2008 Country and setting: Germany, 50% of office-based urologists Enrollment period: September 2004 to November 2005 Funding: Astellas Pharma GmbH Author industry relationship disclosures: 3 of 4 Astellas (3) Bayer (1) Boehringer (1) Elbion (1) Eli Lilly (1) Pfizer (1) | Design: Case series Intervention: Solifenacin 5–10 mg qd × 12 wks (initial dose could be adjusted at first and second follow-up visits) Groups: NA N at enrollment: 4,450 N at follow-up: 4,146 Age, mean ± SD: 63.6 ± 13.1 Weight (kg), mean ± SD: 75.5 ± 12.3 Height (cm), mean ± SD: 167 ± 7 Race/ethnicity: ”the vast majority of OAB patients in Germany are Caucasian” Women, %: 83.5 Follow-up: 12 weeks | Inclusion criteria: • Age ≥ 18 Exclusion criteria: NR | Duration of OAB (years), mean ± SD: 2.9 ± 3.7 Duration of OAB (years), median (range): 1.5 (0–34.6) Previous OAB drug treatment, %: Herbal drugs: 28 Oxybutynin: 23 Trospium chloride: 20 Tolterodine: 13 Topical estrogens: 12 No treatment: 30 Previous non-pharma OAB treatment, %: Absorbent products: 51 Pelvic floor exercises: 41 Bladder training: 22 No treatment: 30 Initial solifenacin dose, %: 5 mg: 93.4 10 mg: 6.1 Final solifenacin dose, %: 5 mg: 78.7 10 mg: 20.8 Heart rate (beats/min), mean ± SD: 75.2 ± 8.2 Blood pressure (mm Hg), mean ± SD: 137 ± 15/82 ± 7 | Mult regression analysis of the presence of trt-emergent AEs, OR (95% CI): Male sex: 0.840 (0.559,1.265) P = 0.4042 Age: NA P = 0.0019 Age 41–50: 1.144 (0.363, 3.608) P = 0.8180 Age 51–60: 1.773 (0.614, 5.119) P = 0.2900 Age 61–70: 1.941 (0.682, 5.524) P = 0.2137 Age 71–80: 1.816 (0.627, 5.262) P = 0.2715 Age > 80: 3.902 (1.327, 11.472) P = 0.0133 BMI (kg/m^2^): NA P = 0.9052 Comedication present: 1.768 (1.219, 2.564) P = 0.0027 CHD/MI present: 0.997 (0.667, 1.491) P = 0.9892 CHF present: 1.243 (0.774, 1.997) P = 0.3684 Diabetes mellitus present: 1.083 (0.762, 1.541) P = 0.6557 Heart rate (beats/min), mean ± SD: 74.5 ± 7.6 Blood pressure (mm Hg), mean ± SD: 134 ± 13/81 ± 8 Treatment-emergent AEs, n (%): 215 (4.8) Leukocyturia, n (%): 48 (1.1) Dry mouth, n (%): 31 (0.7) Haematuria, n (%): 26 (0.6) Constipation, n (%): 20 (0.4) Proteinuria, n (%): 17 (0.4) UTI, n (%): 15 (0.3) Nausea, n (%): 14 (0.3) Nitrate present in urine, n (%): 13 (0.3) Bacteriuria, n (%): 9 (0.2) Glycosuria, n (%): 7 (0.2) Discontinued dt AEs, n (%): 62 (1.4) | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: NA Method and blinding: NA Pt selection criteria: + Loss to followup: ++ Drop-out rates: ++ Power calculation: - Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: NR Baseline characteristics: + Length of followup: ++ Measurement methods: + Measurement reliability: - Intervention description: +
Author: Millard et al., 1999 Country and setting: Australia & US, Academic medical centers Enrollment period: NR Funding: Pharmacia and Upjohn AB Author industry relationship disclosures: NR | Design: RCT Intervention: Tolterodine 1 mg vs. tolterodine 2 mg vs. placebo Groups: G1: tolterodine 1 mg × 12 wks G2: tolterodine 2 mg × 12 wks G3: placebo × 12 wks N at enrollment: G1: 129 G2: 123 G3: 64 N at follow-up: G1: 114 G2: 116 G3: 61 Women, %: G1: 78 G2: 77 G3: 66 Age, mean (range): G1: 60.1 (24–89) G2: 60.2 (24–83) G2: 60.5 (25–84) BMI, kg/m^2^ (range): G1: 28.0 (17.2–47.2) G2: 27.3 (16.6–51.4) G2: 26.8 (19.9–47.1) | Inclusion criteria: • Age ≥ 18 • Cystometrically proved DO • Average urinary frequency ≥ 8 voids/day • UI (≥ 1 incontinence episodes/day) and/or urinary urgency • Adequate contraception Exclusion criteria: • SUI • Voiding difficulty (max flow rate < 10 mL/second with post-void residual volume > 200 mL) • Recurrent UTI • Interstitial cystitis • Hematuria • Bladder cancer • Intermittent catheterization or indwelling catheter • Hepatic or renal disease • Narrow angle glaucoma • Electro- stimulation for bladder training • Started primarily anticholinergic drug ≤ 14 days • Unstable dose of any treatment with anticholinergic side effects • Average total voided volume >3 L/24 h • Treatment with any investigational drug during or 2 mos before study | Urgency, %: G1: 100 G2: 100 G3: 98 Incontinence, %: G1: 88 G2: 90 G3: 86 Incontinence episodes/day, mean ± SD: G1: 3.9 ± 4.0 G2: 3.6 ± 4.0 G3: 3.5 ± 3.2 Incontinence episodes/day, mean (range): G1: 3.9 (0.1–24.0) G2: 3.6 (0.3–24.0) G3: 3.5 (0.1–18.4) ≥ 8 voids/day, %: G1: 99 G2: 98 G3: 98 Voids/day, mean ± SD: G1: 11.5 ± 3.7 G2: 11.2 ± 3.1 G3: 11.3 ± 3.4 Voids/day, mean (range): G1: 11.5 (7.0–26.3) G2: 11.2 (6.3–22.0) G3: 11.3 (7.1–21.7) Duration of symptoms > 5 yrs, %: G1: 44 G2: 49 G3: 47 Detrusor instability, %: G1: 87 G2: 88 G3: 91 Hyper reflexia, %: G1: 13 G2: 12 G3: 9 Severe problems, patient perception, %: G1: 42 G2: 50 G3: 36 Previous therapy for UI, %: G1: 50 G2: 47 G3: 48 Previous therapy for UI, good efficacy response, %: G1: 39 G2: 48 G3: 45 Previous lower urinary tract surgery, %: G1: 35 G2: 33 G3: 30 Voided volume (mL), mean ± SD: G1: 151 ± 56 G2: 155 ± 52 G3: 158 ± 53 Voided volume (mL), mean (range): G1: 151 (34–334) G2: 155 (32–304) G3: 158 (47–299) Bladder volume (mL), initial contraction, mean (range): G1: 167 (4–600) G2: 188 (7–520) G3: 212 (6–600) Post voiding residual volume (mL), mean (range): G1: 28 (0–180) G2: 25 (0–178) G3: 33 (0–200) Max flow rate, (mL/sec), mean (range): G1: 18 (2–56) G2: 20 (3–70) G3: 19 (5–57) Detrusor overactivity ≥ 10 cm, %: G1: 98 G2: 98 G3: 98 Max wave height (cm), mean (range): G1: 44 (2–144) G2: 45 (2–165) G3: 52 (4–188) | Incontinence episodes/day, mean change ± SD (mean % change): G1: −1.7 ± 2.8 (−43) G2: −1.7 ± 2.5 (−50) G3: −1.3 ± 2.5 G1/G3: P = 0.27 G2/G3: P < 0.19 Voids/day, mean change ± SD: G1: −2.3 ± 3.0 (−20) G2: −2.3 ± 2.1 (−25) G3: −1.4 ± 2.3 G1/G3: P = 0.0029 G2/G3: P = 0.045 Patients achieving normalized voiding frequency, %: G1: 26 G2: 43 G3: 26 G2/G3: P = 0.012 G2/G1: P = 0.022 Complete cure, %: G1: 19 G2: 11 G3: 10 Compliance (12 of 14 wks), %: G1: 87 G2: 89 Perceived improvement, %: G1: 41 G2: 59 G3: 38 G2/G3: P = 0.015 G2/G1: P = 0.018 Voided volume (mL), mean change ± SD: G1: 27 ± 41 G2: 36 ± 50 G3: 10 ± 47 G1/G3: P = 0.0059 G2/G3: P < 0.0001 Minor noncholinergic and cholinergic AEs, %: G1: 74 G2: 73 G3: 78 AEs per patient, mean: G1: 1.9 G2: 2.2 G3: 2.0 Autonomic nervous system disorders, %: G1: 29 G2: 43 G3: 17 Dry mouth, %: G1: 24 G2: 39 G3: 13 Dry mouth, severe, %: G1: 1 G2: 2 G3: 2 Dry eyes, %: G1: 2 G2: 6 G3: 2 Serious AEs, n (%): G1: 5 (4) G2: 7 (5) G3: 5 (4) G3: 2 Severe AEs possibly indicating cardiac dysfunction, %: G1: 0 G2: 2 Nonserious cardiac AEs, %: G1: 3 G2: 3 G3: 6 Discontinued due to AEs, n (%): G1: 2 (2) G2: 8 (6) G3: 0 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: + Pt selection criteria: + Loss to followup: ++ Drop-out rates: + Power calculation: + Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Millard, 2004 Country and setting: International, Multicenter study, 54 sites Enrollment period: NR Funding: Pharmacia Corp Author industry relationship disclosures: NR | Design: RCT Intervention: Tolterodine ± simplified pelvic-floor exercise regimen for 24 weeks Groups: G1: tolterodine 2 mg b.i.d. and simple pelvic floor muscle exercise (PFME) program G2: tolterodine 2 mg b.i.d. daily N at enrollment: G1: 227 G2: 253 N at follow-up, 12 weeks, n (%): G1: 181 (79.7) G2: 205 (81.0) N at follow-up, 24 weeks, n (%): G1: 164 (72.2) G2: 190 (75.1) Women, n (%): G1: 169 (75.4) G2: 190 (75.4) Age, mean ± SD: G1: 53.6 ± 16.9 G2: 53.2 ± 17.4 Race/ethnicity: Asian: G1: 176 (78.6) G2: 203 (80.6) White/mixed: G1: 48 (21.4) G2: 49 (19.4) | Inclusion criteria: • Age 18–90 • ≥ 8 voids/day • Urgency • ≥ 1 UI episode/d • sx for ≥ 6 months Exclusion criteria: • Symptomatic SI • Significant PVR volume • Neuropathy • Glaucoma • UTI • + urine cytology • Use of concomitant anticholinergic therapy w/in 14 days of randomization | Urgency episodes/day, mean ± SD: G1: 4.2 ± 3.6 G2: 4.1 ± 4.0 Urgency episodes/day, median (IQR): G1: 3.6 (1.3–6.0) G2: 3.0 (1.3–6.0) Incontinence episodes/day, mean ± SD: G1: 3.44 ± 3.4 G2: 3.21 ± 3.4 Incontinence episodes/day, median (IQR): G1: 2.3 (1.3–4.0) G2: 2.9 (1.3–3.7) Voids/day, mean ± SD: G1: 11.87 ± 4.3 G2: 12.78 ± 5.6 Voids/day, median (IQR): G1: 10.7 (9.0–13.7) G2: 11.3 (9.0–15.0) Voided volume (mL), mean ± SD: G1: 146.1 ± 67.7 G2: 146.0 ± 83.3 Voided volume (mL), median (IQR): G1: 137 (98–186) G2: 132 (99–189) Duration of symptoms, n (%): ≤ 5 years: G1: 166 (74.1) G2: 173 (68.7) > 5 years: G1: 56 (25) G2: 78 (31) Previous UT surgery, n (%): G1: 44 (19.6) G2: 43 (17.1) Prev antichol-inergics, n (%): G1: 19 (8.5) G2: 14 (5.6) Prev UUI drug, n (%): G1: 101 (45.1) G2: 91 (36.1) Patient subjective rating of UI symptoms as “severe” or “many severe”, %: G1: 54.0 G2: 56.8 | Urgency episodes/day, wk 12, mean change ± SD (% change): G1: −1.9 ± 4.0 (−64.5) G2: −2.2 ± 3.6 (−69.8) G1/BL: P = 0.001 G1/BL: P = 0.001 G1/G2: P = NS Urgency episodes/day, wk 12, median change: G1: −1.6 G2: −1.3 G1/G2: P = 0.7658 Urgency episodes/day, wk 24, mean change ± SD (% change): G1: −2.2 ± 3.6 (−78.7) G2: −2.7 ± 3.5 (−83) G1/BL: P = 0.001 G1/BL: P = 0.001 G1/G2: P = NS Urgency episodes/day, wk 24, median change: G1: −1.9 G2: −2.0 G1/G2: P = 0.3029 Incontinence episodes/day, wk 12, mean change ± SD: G1: −2.15 ± 3.0 G2: −2.15 ± 2.7 G1/BL: P = 0.001 G1/BL: P = 0.001 G1/G2: P = 0.2215 Incontinence episodes/day, wk 12, median change: G1: −1.6 G2: −1.6 G1/G2: P = 0.8251 Incontinence episodes/day, wk 24, mean change ± SD (% change): G1: −2.23 ± 3.0 (−64) G2: −2.26 ± 3.0 (−70) G1/BL: P = 0.001 G1/BL: P = 0.001 G1/G2: P = NS Incontinence episodes/day, wk 24, median change: G1: −1.6 G2: −1.6 G1/G2: P = 0.8341 Voids/day, wk 12, mean change ± SD (% change): G1: −2.68 ± 3.8 (−22) G2: −3.42 ± 4.6 (−26) G1/BL: P = 0.001 G1/BL: P = 0.001 G1/G2: P = 0.9478 Voids/day, wk 24, mean change ± SD (% change): G1: −2.58 ± 5.0 (−22) G2: −3.58 ± 5.2(−26) G1/BL: P = 0.001 G1/BL: P = 0.001 G1/G2: P = 0.3549 Voided volume (mL), wk 12, median change (% change): G1: 20.4 (17.2) G2: 17.5 (15.8) Voided volume (mL), wk 12, median change (% change): G1: 21.1 (18.1) G2: 19.1 (15.4) Patient subjective report of improvement in bladder condition, wk 12, %: G1: 82.6 G2: 83.9 Patient subjective report of improvement in bladder condition, wk 24, %: G1: 81.7 G2: 85.9 Adverse events, n (%): G1: 22 (9.7) G2: 23 (9.1) Mild dry mouth, %: G1: 18.1 G2: 21.3 Moderate dry mouth, %: G1: 7.5 G2: 5.1 Severe dry mouth, %: G1: 4.0 G2: 3.2 Headache, %: 6 Constipation, %: 4.8 Nausea, %: 2.7 Dry eyes, %: 2.5 Dizziness, %: 2.4 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: − Pt selection criteria: + Loss to followup: ++ Drop-out rates: − Power calculation: + Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Minassian et al., 2007 Country and setting: Canada, Tertiary care center Enrollment period: February 2003 to December 2005 Funding: Janssen-Ortho Inc. Author industry relationship disclosures: NR | Design: RCT Intervention: Oxybutynin XL vs oxybutynin IR Groups: G1: oxybutynin XL 5 mg qd after 4 weeks non responders to oxybutynin XL 10 mg qd G2: oxybutynin IR 2.5 mg t.i.d. after 4 weeks non responders to oxybutynin 5 mg t.i.d. N at enrollment: G1: 39 G2: 33 N at follow-up: G1: 35 G2: 27 Age, mean ± SD: G1: 75 ± 6 G2: 73 ± 5 Women, %: G1: 100 G2: 100 Race/ethnicity: NR Height, cm ± SD: G1: 158 ± 6 G2: 159 ± 5 Weight, kg ± SD: G1: 73 ± 14 G2: 76 ± 14 BMI, kg/m^2^ ± SD: G1: 29 ± 5 G2: 30 ± 5 Parous, %: G1: 85 G2: 88 | Inclusion criteria: • Symptoms of OAB (ICS) • Female • Age > 65 • Community-dwelling • OAB main presenting symptom, 2-week washout if on anticholinergic medication Exclusion criteria: • Bedridden • Permanent indwelling catheter • MMSE score <24 • Glaucoma • Gastric retention or bowel obstruction • History of allergy to anticholinergic medications • Taking tricyclic antidepressants or anticho-linesterase inhibitors • Post-void residual bladder volume >100 mL • History of neurologic disorder | UUI, %: G1: 95 G2: 94 SUI, %: G1: 67 G2: 52 Urgency, %: G1: 100 G2: 97 Incontinence episodes/day, median (IQR): G1: 2 (0, 4) G2: 1 (0, 3) Frequency episodes/day, median (IQR): G1: 9 (7, 11) G2: 10 (8, 12) Voids/day, median (IQR): G1: 13 (10, 16) G2: 14 (11, 16) Nocturia episodes/day, median (IQR): G1: 2 (2, 3) G2: 3 (2, 4) Pads/day, median (IQR): G1: 1 (0, 3) G2: 1 (0, 3) Mini-mental state exam, median score (IQR): G1: 29 (29, 30) G2: 30 (28, 30) U-IIQ, activities score ± SD: G1: 2.7 ± 0.9 G2: 3.1 ± 1.1 U-IIQ, travel score ± SD: G1: 2.4 ± 1.3 G2: 2.8 ± 1.6 U-IIQ, physical activities score ± SD: G1: 2.4 ± 1.2 G2: 2.6 ± 1.5 U-IIQ, feelings score ± SD: G1: 2.5 ± 1.2 G2: 2.7 ± 1.5 U-IIQ, relationships score ± SD: G1: 1.7 ± 0.6 G2: 2.0 ± 1.4 U-UDI, mean score ± SD: G1: 2.9 ± 0.6 G2: 2.7 ± 0.8 Voided volume (mL), median (IQR): G1: 142 (109, 192) G2: 138 (108, 165) Postvoid residual volume (mL), median (IQR): G1: 0 (0, 23) G2: 0 (0, 22) Urine culture positive, % G1: 8 G2: 9 Previous prolapse/incontinence surgery, %: G1: 13 G2: 49 Positive cough test, lying, %: G1: 26 G2: 15 Positive cough test, standing, %: G1: 33 G2: 15 | Incontinence episodes/day, 12 wks, median (IQR): G1: 1 (0, 2) G2: 0 (0, 1) P = 0.05 Frequency episodes/day, wk 1–12, median change (IQR): G1: −1.4 (−3.3, 0.4) G2: −1.3 (−4.1, 0.3) P = 0.65 Voids/day, wk 12, median (IQR): G1: 11 (9, 13) G2: 11 (9, 14) P = 0.35 Pads/day, 12 wks, median (IQR): G1: 0 (0, 2) G2: 0 (0, 1) P = 0.53 U-IIQ, activities score ± SD: G1: 2.2 ± 1.0 G2: 2.1 ± 1.2 P = 0.73 U-IIQ, travel score ± SD: G1: 2.0 ± 1.1 G2: 1.9 ± 1.2 P = 0.79 U-IIQ, physical activities score ± SD: G1: 2.3 ± 1.3 G2: 1.9 ± 1.2 P = 0.45 U-IIQ, feelings score ± SD: G1: 2.0 ± 1.1 G2: 1.9 ± 1.3 U-IIQ, relationships score ± SD: G1: 1.4 ± 0.9 G2: 1.5 ± 1.0 U-UDI, mean score ± SD: G1: 2.1 ± 1.0 G2: 1.7 ± 1.0 P = 0.10 Voided volume (mL), 12 wks, median (IQR): G1: 164 (129, 187) G2: 161 (114, 109) P = 0.78 Postvoid residual volume (mL), 12 wks, median (IQR): G1: 0 (0, 29) G2: 4 (0, 87) P = 0.33 Remained on med, 12 wks, %: G1: 70 G2: 61 P = 0.42 Experienced side effects, %: G1: 51 G2: 57 Dry mouth, n: G1: 14 G2: 16 Gastro-intestinal, n: G1: 6 G2: 2 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: − Pt selection criteria: + Loss to followup: + Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Molander et al., 1991 Country and setting: Sweden, Academic hospital Enrollment period: NA Funding: Goteborg Medical Society, University of Goteborg Author industry relationship disclosures: NR | Design: Case series Intervention: 3mg estriol qd for 1 mo, then 1–2 mg estriol qd for 2 mos Groups: G1: Intervention among SUI G2: Intervention among UUI G3: Intervention among MUI N at enrollment: G1: 91 G2: 113 G3: 142 N at follow-up: G1: 55 G2: 69 G3: 82 Women, %: 100 Age, mean (SE): G1: 70.1 (1.9) G2: 73.5 (1.2) G3: 72.6 (1.3) Race/ethnicity: NR Parity, mean (SE): G1: 2.0 (0.2) G2: 1.7 (0.1) G3: 1.9 (0.1) Menopausal age, mean (SE): G1: 49.6 (0.4) G2: 49.1 (0.4) G3: 48.8 (0.5) | Inclusion criteria: • Self-reported UI (with UUI defined as involuntary urine loss preceded by the urge to void or uncontrollable voiding with little or no warning; SUI definded as involuntary urinary loss precipitated by coughing, sneezing, or physical exertion; and MUI defined as a combination of UUI+SUI) Exclusion criteria: NR | Total leakage/48 hours (mL), mean (SEM): G1: 25.2 (6.1) G2: 44.4 (9.8) G3: 65.1 (11.5) Max single leakage/48 hours, mean (SE): G1: 14.0 (3.1) G2: 21.7 (3.6) G3: 31.5 (3.1) Voids/day, mean (SE): G1: 6.9 (0.3) G2: 8.4 (0.3) G3: 7.6 (0.3) Total voided volume/day (mL), mean (SE): G1: 1405 (68) G2: 1515 (71) G3: 1497 (68) Max voided volume (mL)/day, mean (SE): G1: 401 (22) G2: 396 (23) G3: 383 (18) | Total leakage/48 hours (mL), mean (SEM): G1: 19.7+/− 6.1 G2: 37.3+/− 11.9 G3: 26.2+/− 6.8 G3/BL: P < 0.01 Max single leakage/48 hours, mean (SE): G1: 11.3 (3.1) G2: 19.2 (4.6) G3: 16.1 (4.2) G3/BL: P < 0.05 Voids/day, mean (SE): G1: 7.1 (0.4) G2: 7.9 (0.4) G3: 7.4 (0.4) G2/BL: P < 0.05 Total voided volume/day (mL), mean (SE): G1: 1539 (67) G2: 1481 (74) G3: 1483 (88) Max voided volume (mL)/day, mean (SE): G1: 438 (24) G2: 399 (27) G3: 392 (26) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: − Drop-out rates: + Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Moore et al., 1990 Moore and Sutherst, 1990^*^ Country and setting: UK, academic health center Enrollment period: NR Funding: Tillots Laboratories NR^*^ Author industry relationship disclosures: NR | Design: RCT with crossover Intervention: oxybutynin hydrochloride vs placebo Groups: G1:oxybutynin hydrochloride 3 mg t.i.d. G2:placebo N at enrollment: 53 N at follow-up: G1: 27 G2: 22 Age, mean ± SD: G1: 46.0 ± 11.7 G2: 46.4 ± 12.4 Race/ethnicity: NR Parity, mean: G1: 2.3 G2: 2.2 | Inclusion criteria: • UDS-defined idiopathic detrusor instability • Involuntary detrusor contractions > 30 cm H2O during filling phase of cystometry Exclusion criteria: • Neurological disorder • Urologic disorder • Age > 75 years • Genuine SI • Low-compliance bladder • Bacterial or interstitial cystitis • Previous treatment with oxybutynin | Voids/day, mean ± SD: G1: 11.1 ± 7.9 G2: 12.1 ± 5.7 Volume at first desire to void mean mL ± SD: G1: 94.2 ± 66 G2: 107.4 ± 101 Max detrusor filling pressure mean cm H2O, ±SD: G1: 55.3 ± 23 G2: 59.2 ± 26 Max cystometric capacity (mL) G1: 275 ± 164 G2: 290 ± 168 Residual urine volume mean mL ± SD: G1: 23.1 ± 34.2 G2: 22.7 ± 34.0 Duration of OAB, mean yrs ± SD): G1: 7.5 ± 7.9 G2: 8.9 ± 9.0 | Change in volume at first desire to void, period 1, mean mL ± SD (95% CI) G1: 70.0 ± 103 G2: 7.7 ± 76 G1/G2: P = 0.02 95% CI: (10, 113) Change in maximum detrusor filling pressure, mean ± SD: G1: − 16.9 ± 19.5 G2:1.0 ± 28.7 G1/G2: P = 0.02 95% CI: (− 32.5, − 3.2) Change in maximum cystometric capacity, mean ± SD: G1:104.0 ± 131 G2:7.0 ± 103 G1/G2: P = 0.006 95% CI: (29, 165) Change in residual urine Volume, period 1: G1: 22.4 (79.3) G2: 7.7 (45.7) P = 0.42 Change in residual urine Volume, period 2: G1: 10.0 ± 27.1 G2: 25.7 ± 55.6 P = 0.33 Dry mouth on oxybutynin, %: 88 Dry mouth on placebo, %: 33 Mouth ulcers on oxybutynin, %: 16 Mouth ulcers on placebo, %: 0 Constipation on oxybutynin, % 12.5 Constipation on placebo, % 0 Drowsiness on oxybutynin, %: 12.5 Drowsiness on placebo, %: 7 Nausea on oxybutynin, %: 8.3 Nausea on placebo, %: 2.3 Initial hesitancy on oxybutynin, %: 4.2 Initial hesitancy on placebo, %: 2.3 Dizziness on oxybutynin, %: 4.2 Dizziness on placebo, %: 7.0 Metallic taste on oxybutynin, %: 2.4 Metallic taste on placebo, %: 2.3 Crown Crisp Experimental Index, >50% improvement:^*^ Free floating anxiety: 6.4 Phobic anxiety: 5.3Obsessionalism: 6.2 Somatic complaints: 6.2 Depression: 4.0 Hysteria: 2.6 Total: 30.7 Crown Crisp Experimental Index, <49% improvement:^*^ Free floating anxiety: 8.8 Phobic anxiety: 6.8 Obsessionalism: 8.1 Somatic complaints: 8.9 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Nitti et al.,2007 Country and setting: US, 83 center Enrollment period: October 2003 to February 2005 Funding: Schwarz BioSciences GmbH and Pfizer, Inc Author industry relationship disclosures: 9 of 9 Allergan (3) Astellas (3) Gynecare (1) Novartis (2) Pfizer (5) Boston Scientific (1) Espirit (4) Ortho (1) Watson (1) Indevus (1) GlaxoSmithKline (1) Schwarz Biosciences (3) | Design: RCT Intervention: Placebo, Fesoteorine 4 or 8 mg, bladder diary before randomization, 2, 8, 12 wks Groups: G1: Placebo G2: Fesoterodine 4 mg/d G3: Fesoterodine 8 mg/d N at enrollment: Total: 836 G1: 274 G2: 283 G3: 279 N at follow-up: G1: 266 G2: 267 G3: 267 Age, mean (range): Total: 59 (21, 91) G1: 59 (24, 88) G2: 59 (21, 85) G3: 59 (23, 91) Women, %: Total: 76 G1: 74 G2: 76 G3: 78 Race/ethnicity: White: Total: 82% G1: 80% G2: 82% G3: 84% Black: G1: 10% G2: 9% G3: 8% Asian: G1: 2% G2: 1% G3: 1% | Inclusion criteria: • Age ≥ 18 • Urinary frequency ≥8 voids/day • Urgency ≥ 6 for 3 days or UUI ≥ 3 episodes/3 day diary • At least moderate bladder problems on a Likert scale Exclusion criteria: Pregnant Women of reproductive age not on adequate contraception Lower urinary tract pathology (SUI, urolithiasis, interstitial cystitis, urothelial tumors, ≥ grade 3 pelvic organ prolapse, BOO, postvoid residual > 100 mL, polyuria >3 L/24 h, rec UTI) Current antimuscarinic Neurogenic cause for OAB Arrhythmia Unstable angina or corrected QT interval > 500 ms Electrostimulation or bladder training in past 4 weeks or currently | UUI episodes/day, mean ± SD: G1: 3.7 ± 3.3 (n=205) G2: 3.9 ± 3.5 (n=228) G3: 3.9 ± 3.3 (n=218) Urgency episodes/day, mean ± SD: G1: 11.4 ± 3.8 G2: 12.5 ± 4.1 G3: 11.6 ± 3.7 Incontinence, n (%): G1: 205 (77) G2: 228 (85) G3: 218 (82) Continent days/wk, mean ± SD: G1: 0.6 ± 1.3 G2: 0.7 ± 1.5 G3: 0.7 ± 1.4 Voids/day, mean ± SD: G1: 12.2 ± 3.7 G2: 12.9 ± 3.9 G3: 12.0 ± 3.3 Daytime voids/day, mean ± SD: G1:10.2 ± 3.3 G2: 10.7 ± 3.4 G3: 10.1 ± 2.9 Nocturia episodes/day, mean ± SD: G1: 2.0 ± 1.3 G2: 2.2 ± 1.6 G3: 1.9 ± 1.4 Voided volume (mL), mean ± SD: G1: 159 ± 69 G2: 152 ± 60 G3: 156 ± 58 Years since OAB diagnosis, mean ± SD: G1: 9.8 ± 10.3 G2: 9.1 ± 10.3 G3: 10.1 ± 11.5 Previous tolterodine use, n (%): G1: 90 (33) G2: 88 (31) G3: 95 (34) Previous oxybutynin use, n (%): G1: 101 (37) G2: 94 (33) G3: 97 (35) Previous trospium chloride use, n (%): G1: 7 (2.6) G2: 6 (2.1) G3: 3 (1.1) | UUI episodes/day, LS mean change (SE): G1: −0.96 (0.17) G2: −1.65 (0.16)* G3: −2.28 (0.16)* UUI episodes/day, median % change: G1: −40.0 (n=205) G2: −67.4* (n=228) G3: −81.8* (n=218) Urgency episodes/day, LS mean change (SE): G1: −0.79 (0.20) G2: −1.91 (0.20) G3: −2.30 (0.20) Urgency episodes/day, median % change: G1:−3.3 G2: −16.3* G3: −18.4* Continent days/wk, LS mean change (SE): G1: 1.31 (0.20) G2: 2.33 (0.19)* G3: 2.80 (0.19)* Voids/day, LS mean change (SE): G1: −1.08 (0.18) G2: −1.61 (0.18)* G3: −2.09 (0.18)* Voids/day, mean % change: G1: −6.9 G2: −14.9* G3: −16.0* Daytime voids/day, LS mean change (SE): G1: −0.69 (0.16) G2: −1.04 (0.16) (P = 0.107) G3: −1.54 (0.16)* Daytime voids/median % change: G1: −5.9 G2: −11.1 (P = 0.008) G3: −15.6* Nocturia episodes/day, LS mean change (SE): G1: −0.39 (0.07) G2: −0.58 (0.17) (P = 0.042) G3: −0.55 (0.17) (P = 0.09) Nocturia episodes/day, median % change: G1: −25.0 G2: −33.3 (P = 0.013) G3: −25.0 (P = 0.267) Treatment response, n (% yes) G1: 266 (45) G2: 267 (64)* G3: 267 (74)* Voided volume (mL), LS mean change (SE): G1: 8.38 (4.06) G2: 16.5 (4.00) (P = 0.15) G3: 33.6 (4.04)* Side effects, n (%): G1: 149 (55) G2: 171 (61) G3: 193 (69) Dry mouth, n (%): G1: 19 (7) G2: 45 (16) G3: 99 (36) Constipation, n (%): G1: 7 (3) G2: 14 (5) G3: 21 (8) UTI, n (%): G1: 11 (4) G2: 10 (4) G3: 15 (5) Headache, n (%): G1: 9 (3) G2: 12 (4) G3: 8 (3) Withdrew, %: Total: 19 G1: 41 G2: 58 G3: 56 Withdrew due to AE, %: G1: 4 G2: 6 G3: 9 *P < 0.001 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: ++ Drop-out rates: − Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Preik et al., 2004 [See evidence table for Anderson et al. 1999] Country and setting: Germany & US, Multiple academic hospitals Enrollment period: NR Funding: ALZA Corporation Author industry relationship disclosures: 4 of 5 ALZA Corp (2) Ditropan XL (1) Janssen-Cilag GmbH (1) Johnson and Johnson (1) Ortho-McNeil (1) | Design: RCT Intervention: Oxybutynin Groups: daily dose increased in 5 mg increments each 4–7 days until reaching the minimum effective dose, maximum tolerated dose, or maximum allowable dose. Once participant reached titrated dose, maintained for 1 week confirmation period and 1 week maintenance period. G1: Controlled-release oxybutynin (OROS-O) G2: Immediate release oxybutynin (IR-O) N at enrollment: 105 N at follow-up: Total: 93 G1: 46 G2: 47 Women, n (%): G1: 50 (94.3) G2: 47 (90.4) Age, mean (SE): G1: 59.2 (10.6) G2: 59.6 (10.0) Race/ethnicity: NR Weight (kg), mean (SE): G1: 78.0 (18.3) G2: 80 (20.2) | Inclusion criteria: • Community-dwelling men & women age 40–75 • Urge or mixed UI • ≥ 6 UUI episodes per week recorded on the run-in diary after washout of anticholinergic • Previous response to anticholinergic • Urge predominant SUI Exclusion criteria: • Known treatable GU disorders that could cause incontinence • Men who had had prostate surgery < 9 mos before study enrollment or with a PSA level of >10 ng/mL • PVR of > 100mL • Estimated Cr clearance of < 50 mL/min • Glaucoma or untreated anterior chamber angles • Hgb < 100g/L • Known hyper-sensitivity to oxybutynin • History of drug or alcohol abuse • Positive urine drug screen • Pregnant or breastfeeding • Myasthenia gravis | UUI episodes/wk, mean (SE): G1: 27.6 (24.0) G2: 23.4 (16.3) Duration of incontinence, n (%): 1–5 years: G1: 26 (49) G2: 22 (42) > 5 years: G1: 23 (43) G2: 22 (42) | Dose-titration endpoint, MED, n/N (%): G1: 29/46 (63) G2: 26/47 (55) Dry mouth, MED, n/N (%): G1: 3/29 (10) G2: 7/26 (27) Dose-titration endpoint, MTD, n/N (%): G1: 11/46 (24) G2: 19/47 (41) Dry mouth, MTD, n/N (%): G1: 7/11 (64) G2: 13/19 (68) Dose-titration endpoint, MAD, n/N (%): G1: 6/46 (13) G2: 2/47 (4) Dry mouth, MAD, n/N (%): G1: 1/6 (17) G2: 1/2 (50) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: − Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: − Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Rentzhog et al., 1993 Country and setting: Sweden & UK, 17 academic hospitals Enrollment period: NR Funding: Pharmacia & Upjohn AB Author industry relationship disclosures: NR | Design: RCT, double blind, placebo controlled Intervention: tolterodine vs placebo Groups: G1: tolterodine 1mg/d G2: tolterodine 2 mg/d G3: tolterodine 4mg/d G4: tolterodine 8mg/d G5: placebo N at enrollment: G1: 21 G2: 16 G3: 14 G4: 16 G5: 13 N at follow-up: G1: 17 G2: 15 G3: 11 G4: 11 G5: 10 Women, n: G1: 14 G2: 10 G3: 12 G4: 15 G5: 10 Age, mean: G1: 56 G2: 59 G3: 56 G4: 58 G5:58 Race/ethnicity: NR Body weight, kg, mean: G1: 73 G2: 76 G3: 72 G4: 76 G5: 73 | Inclusion criteria: • age 18–75 • urinary urgency, 8+ micturitions/d, and/or UI (1+ episode/d) • UDS-confirmed detrusor instabililty (phasic increase in detrusor pressure in the presence of typical sx) • max urinary flow rate of >15 mL/s • sterile or clinically insignificant bacteriuria • normal routine laboratory tests Exclusion criteria: • antimuscarinic agents or drugs w/antimuscarinic side effects • other drugs for UI (except estrogens) • clinically significant cardiac, hepatic, renal, or heme disorders • contraindications to antimuscarinic agents • pregnant or lactating • women not using reliable contraception | Frequency of micturitions/d: G1: 10.3 G2: 11.2 G3: 12.8 G4: 10.2 G5: 10.2 Incontinence episodes/d: G1: 2.1 G2: 1.7 G3: 1.8 G4: 2.7 G5: 4.1 Previous drug therapy: G1: 9 G2: 10 G3: 9 G4: 9 G5: 4 Frequency, n: G1: 7 G2: 7 G3: 4 G4: 5 G5: 4 Leakage, n: G1: 2 G2: - G3: 2 G4: 1 G5: 3 Leakage and frequency, n: G1: 11 G2: 9 G3: 7 G4: 9 G5: 6 Volume at first contraction (mL), mean mL ± SD G1: 243 ± 220 G2: 274 ± 129 G3: 171 ± 109 G4: 297 ± 123 G5: 295 ± 16723 ( Residual urinary volume, mean mL ± SD: G1: 24 ± 31 G2: 51 ± 94 G3: 25 ± 18 G4: 52 ± 130 G5: 26 ± 35 Max cystometric capacity, mean mL ± SD: G1: 381 ± 200 G2: 397 ± 197 G3: 284 ± 195 G4: 335 ± 145) G5: 377 ± 181) Bladder compliance, mean mL/cmH2O ± SD: G1: 65 ± 105 G2: 50 ± 44 G3: 36 ± 43 G4: 44 ± 46 G5: 44 ± 28 # detrusor contractions >10 cmH20, mean ± SD: G1: 4.1 ± 3.3 G2: 2.3 ± 1.8 G3: 3.4 ± 2.5 G4: 3.3 ± 2.7 G5: 3.1 ± 3.0 Max urinary flow, mean mL/s ± SD: G1: 21.0 ± 7.5 G2: 2.33 ± 9.9 G3: 19.2 ± 9.8 G4: 20.5 ± 8.2 G5: −2.0 ± 28 Volume at normal desire to void, mean mL ± SD: G1: 235 ± 128 G2: 273 ± 121 G3: 143 ± 83 G4: 211 ± 128 G5: 255 ± 157 Concomitant dz, n: G1: 11 G2: 11 G3: 7 G4: 11 G5: 9 | Volume at first contraction (mL), mean change (% change): G1: 74 (63) G2: 17 (17) G3: 89 (114) G4: 115 (119) G5: −23 (−4) Linear regression of change: P = 0.0459 Residual urinary volume (mL), mean change (% change): G1: 6 (2) G2: 10 (57) G3: 30 (122) G4: 143 (225) G5: 4 (126) Linear regression of change: P = 0.0003 Max cystometric capacity (mL), mean change (% change): G1: 15 (20) G2: −25 (5) G3: 2 (10) G4: 76 (30) G5: −17 (3) Linear regression of change: P = 0.0921 Bladder compliance (mL/cmH2O), mean change (% change): G1: −29 (−9) G2: 10 (164) G3: 2 (72) G4: 18 (355) G5: −6 (11) Linear regression of change: P = 0.1646 Detrusor contractions >10 cmH_2_O, mean change (% change): G1: −1.6 (−34) G2: −1.2 (−38) G3: −2.0 (−33) G4: −0.3 (−32) G5: 0.0 (48) Linear regression of change: P = 0.7284 Max urinary flow (mL/s), mean change (% change): G1: 1.2 (9) G2: 1.3 (18) G3: −2.4 (−3) G4: −0.3 (−32) G5: −2.0 (28) Linear regression of change: P = 0.3072 Volume at normal desire to void (mL), mean change (% change): G1: −1 (2) G2: −18 (1) G3: 32 (25) G4: 66 (45) G5: −18 (15) Linear regression of change: P = 0.0492 Patients reporting 1+ adverse event, n: G1: 8 G2: 6 G3: 7 G4: 12 G5: 6 Total AE reported: G1: 10 G2: 14 G3: 10 G4: 25 G5: 10 Dry mouth G1: 2 G2: 2 G3: 5 G4: 9 G5: 2 Constipation G1: 1 G2: 3 G3: 1 G4: 2 G5: 0 Abnormal vision G1: 0 G2: 3 G3: 1 G4: 1 G5: 1 Urinary retention G1:0 G2: 0 G3: 0 G4: 1 G5: 0 Other G1: 7 G2: 6 G3: 3 G4: 12 G5: 7 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Methods and blinding: + Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Robinson et al., 2007 Country and setting: 12 countries in Europe, 39 study sites Enrollment period: July 2002 to December 2002 Funding: Astellas Author industry relationship disclosures: 2 of 4 Astellas (2) | Design: RCT Intervention: tamsulosin OCAS (0.25, 0.5, 1.0, 1.5 mg) qd vs tolterodine ER qd vs placebo qd Groups: G1: 0.25 mg tamsulosin OCAS qd G2: 0.5 mg tamsulosin OCAS qd G3: 1.0 mg tamsulosin OCAS qd G4: 1.5 mg tamsulosin OCAS qd G5: tolterodine ER qd G6: placebo qd N at enrollment: G1: 58 G2: 65 G2: 63 G4: 60 G5: 61 G6: 61 N at follow-up: G1: 52 G2: 61 G3: 55 G4: 46 G5: 53 G6: 59 Women, %: 100 Age, range: 18–70 Race/ethnicity: NR | Inclusion criteria: • Symptoms of OAB ≥ 3 months Exclusion criteria: • SUI or MUI where stress symptoms predominant and neurogenic | Urgency episodes/day, mean: G1: 5.83 G2: 5.58 G3: 5.82 G4: 6.28 G5: 6.78 G6: 5.58 Incontinence episodes/day, mean: G1: 3.22 G2: 2.17 G3: 3.33 G4: 2.98 G5: 2.33 G6: 2.90 Voids/day, mean: G1: 12.20 G2: 11.09 G3: 12.96 G4: 12.46 G5: 13.22 G6: 11.90 Nocturia episodes/day, mean: G1: 1.97 G2: 1.76 G3: 1.82 G4: 2.10 G5: 2.34 G6: 1.87 Voided volume (mL), mean: G1: 135.5 G2: 148.6 G3: 135.1 G4: 131.4 G5: 148.9 G6: 145.5 | Urgency episodes/day, mean change: G1: −1.51 G2: −1.66 G3: −1.83 G4: −1.91 G5: −2.49 G6: −1.86 G4/G6: P = 0.901 G5/G6: P = 0.632 Incontinence episodes/day, mean change: G1: −1.40 G2: −0.93 G3: 0.02 G4: −0.66 G5: −1.66 G6: −0.66 G4/G6: P = 0.945 G5/G6: P = 0.025 Voids/day, mean change: G1: −1.60 G2: −1.01 G3: −1.38 G4: −1.18 G5: −2.59 G6: −1.81 G4/G6: P = 0.189 G5/G6: P = 0.353 Nocturia episodes/day, mean change: G1: −0.35 G2: −0.36 G3: −0.33 G4: −0.34 G5: −0.74 G6: −0.41 G4/G6: P = 0.495 G5/G6: P = 0.353 Void volume (mL), mean change: G1: 13.9 G2: 9.7 G3: 12.6 G4: 12.9 G5: 24.3 G6: 11.4 G4/G6: P = 0.992 G5/G6: P = 0.092 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: − Drop-out rates: NR Power calculation: + Statistical issues: + EXTERNAL VALIDITY: fair Age: −, NR Baseline OAB status: + Baseline characteristics: − Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Rogers et al., 2008 Country and setting: USA, multicenter (54 outpatient sites) Enrollment period: NR Funding: Pfizer Author industry relationship disclosures: 7 of 7 Bayer (1) Boeringer Ingelheim(1) Duramed (1) J&J (1) P&G (1) Novartis (1) Novo-Nordisk (1) Pfizer (7) Wyeth (1) | Design: Multicenter randomized placebo-controlled double-blind Intervention: Tolterodine 4 mg ER vs placebo within 4 hours of bedtime Groups: G1: Tolterodine 4mg ER daily G2: Placebo N at enrollment: G1: 202 G2: 211 N at follow-up: G1: 163 G2: 167 Women, %: Total: 100 Age, yrs ± SD: G1: 49 ± 12 G2: 47 ± 12 Race/ethnicity, n (%): White: G1: 139 (69) G2: 138 (66) Black: G1: 37 (18) G2: 45 (21) Asian: G1: 3 (2) G2: 4 (2) Other: G1: 22 (11) G2: 23 (11) Parrous, %: G1: 86 G2: 91 Follow-up: 12 weeks Premenopausal, n (%): G1: 71 (35) G2: 95 (45) Perimenopausal, n (%): G1: 18 (9) G2: 16 (8) Postmeno-pausal, n (%): G1: 112 (56) G2: 99 (47) | Inclusion criteria: • Age ≥ 18 • Women •≥ 0.6 UUI episodes/day •≥ 8 voids/day •≥ 3 OAB voids/day (urgency- associated voids) • “some moderate problems” on PPBC • OAB symptoms ≥ 3 months • Stable, sexually active relationship with man ≥ 6 months Exclusion criteria: • POP Stage 3 or greater • History of lower urinary tract surgery • Lifelong sexual dysfunction unrelated to lifelong UUI • Predominate SUI | UUI episodes/day, mean ± SD: G1: 2.5 ± 2.1 G2: 2.2 ± 1.8 Voids/day, mean ± SD: G1: 13.0 ± 4.1 G2: 12.5 ± 3.9 OAB voids/day, mean ± SD: G1: 10.6 ± 4.4 G2: 9.9 ± 4.2 Pads/day, mean ± SD: G1: 2.9 ± 2.7 G2: 2.9 ± 3.1 SQOL-F total score, mean± SD: G1: 69.6 ± 23.1 G2: 69.2 ± 23.0 PISQ total score, mean ± SD: G1: 88.7 ± 13.9 G2: 88.9 ± 14.2 PISQ Behavioral/emotive score, mean ± SD: G1: 38.0 ± 8.9 G2: 38.0 ± 9.0 PISQ Physical score, mean ± SD: G1: 31.7 ± 5.9 G2: 31.8 ± 6.0 PISQ partner related score, mean ± SD: G1: 19.0 ± 2.8 G2: 19.0 ± 2.5 HAD Anxiety score, mean ± SD: G1: 8.3 ± 4.0 G2: 8.2 ± 4.0 HAD Depression score, mean ± SD: G1: 5.1 ± 3.3 G2: 5.4 ± 3.4 | UUI episodes/day, mean change (SE): G1: 1.8 (0.1) G2: 1.4 (0.1) P = 0.0029 (P = 0.0525 when a single statistical outlier is excluded) UUI episodes/day, median % change: G1: −100.0 G2: −82.5 P = 0.0003 No UUI events, week 12, %: G1: 57 G2: 42 P < 0.004 OAB voids/day, mean change (SE): G1: −4.7 (0.3) G2: −3.0 (0.3) P < 0.0001 Pads/day, mean change (SE): G1: −1.5 (0.1) G2: −1.0 (0.1) P = 0.0024 Voids/day, mean change (SE): G1: −3.3 (0.2) G2: −2.3 (0.2) P = 0.0006 SQOL-F score, mean change (SE): G1: 6.4 (1.2) G2: 1.5 (1.2) P = 0.004 PISQ total score, mean change (SE): G1: 4.9 (0.7) G2: 2.3 (0.7) P = 0.009 PISQ behavioral/emotive score, mean change (SE): G1: 1.6 (0.4) G2: 0.5 (0.4) P = NS PISQ physical score, mean change (SE): G1: 2.6 (0.3) G2: 1.6 (0.3) P ≤ 0.01 PISQ partner related score, mean change (SE): G1: 0.6 (0.1) G2: 0.3 (0.1) P = NS HAD anxiety score, mean change (SE): G1: −1.9 (0.3) G2: −1.1 (0.3) P = 0.03 HAD depression score, mean change (SE): G1: −1.2 (0.2) G2: −0.8 (0.2) P = NS Subjects with adverse events, n (%): G1: 114 (57) G2: 111 (53) Withdrawn due to AEs, n (%): G1: 9 (5) G2: 6 (3) Dry mouth, n (%): G1: 26 (13) G2: 19 (9) Constipation, n (%): G1: 7 (4) G2: 8 (4) Nasopharyngitis, n (%): G1: 9 (5) G2: 10 (5) Sinusitis, n (%): G1: 8 (4) G2: 9 (4) URI, n (%): G1: 9 (4) G2: 9 (5) UTI, n (%): G1: 12 (6) G2: 5 (2) Headache, n (%): G1: 7 (4) G2: 6 (3) Depression, n (%): G1: 5 (3) G2: 0 (0) Insomnia, n (%): G1: 5 (3) G2: 0 (0) | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: + Method and blinding: + Pt selection criteria: + Loss to followup: − Drop-out rates: + Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Rudy et al., 2006 Rudy et al., 2006* Staskin and Harnett, 2004† Country and setting: US, 52 sites Enrollment period: NR Funding: Indevus NR† Author industry relationship disclosures: 5 of 5 Indevus (5) NR† | Design: RCT Intervention: Trospium chloride vs placebo × 12 wks Groups: G1: trospium chloride 20 mg b.i.d. G2: matching placebo N at enrollment: G1: 329 G2: 329 N at follow-up: G1: 323 G2: 325 Age, mean (SE): G1: 61.1 (0.69) G2: 61.0 (0.70) Women, N (%): G1: 269 (81.8) G2: 267 (81.2) Race/ethnicity, n (%): Black: G1: 26 (7.9) G2: 21 (6.4) White: G1: 284 (86.3) G2: 300 (91.2) Hispanic: G1: 13 (4.0) G2: 5 (1.5) Asian: G1: 5 (1.5) G2: 3 (0.9) Parity: NR | Inclusion criteria: • Age ≥ 18 • ≥ 6 mos of OAB sx • ≥ 10 voids/day • Sx of urgency • ≥ 7 UUI episodes/wk Exclusion criteria: • Predominantly SUI, insensate UI, or overflow UI • Neurogenic bladder d/o’s • Significant renal dz • Uninvestigated hematuria • UTI at washout or more than 2x during the prior 12 mos • PVR >100mL • Use of any anticholinergic drug or other drug therapy for OAB w/in 21 days before randomization • Bladder surgery w/in 6 mos before randomization • Cancer • Interstitial cystitis • PSA >10ng/mL • Diuretic use • Estrogen therapy • Nonmedical bladder therapy not part of a stable, long-term program (ie, timed voids and straight caths; Kegels were allowed) • Pregnancy • Contraindication to antimuscarinic therapy | UUI episodes/day, median: G1: 2.86 G2: 2.86 P = 0.9849 Urgency severity score associated with toilet voids, median: G1: 1.79 G2: 1.75 P = 0.4100 Voids/day, mean: G1: 12.94 G2: 13.17 P = 0.3169 Nocturia episodes/day, median: G1: 2.00 G2: 2.00 P = 0.9048 Nocturnal urgency severity score associated with toilet voids, mean: G1: 2.03 G2: 2.01 P = 0.6863 OAB-SCS, median: G1: 36.56 G2: 36.88 P = 0.7176 Stanford Sleepiness Scale, mean G1: 1.98 G2: 1.94 Stanford Sleepiness Scale, age group < 65 years: G1: 1.99 G2: 2.09 Stanford Sleepiness Scale, age group > 65 years: G1: 1.96 G2: 1.71 Stanford Sleepiness Scale, age group < 75 years: G1: 2 G2: 1.97 Stanford Sleepiness Scale, age group >75 years: G1: 1.86 G2: 1.79 Voided volume (mL), mean: G1: 154.80 ± NR G2: 154.64 ± NR P = 0.9667 Prior OAB medications, n (%): G1: 162 (49.2) G2: 169 (51.4) Prior hx of pelvic-floor training, n (%): G1: 62 (18.8) G2: 76 (23.1) Currently practice undergarment change d/t incontinence, n (%): G1: 227 (69.0) G2: 239 (72.6) | UUI episodes/day, day 1, median change: G1: −1.00 G2: −0.57 P = 0.042 UUI episodes/day, day 2, median change: G1: −1.29 G2: −0.86 P = 0.0022 UUI episodes/day, day 3, median change: G1: −1.57 G2: −0.86 P < 0.0001 UUI episodes/day, day 4, median change: G1: −1.57 G2: −1.00 P < 0.0001 UUI episodes/day, day 5, median change: G1: −1.57 G2: −1.00 P < 0.0001 UUI episodes/day, day 6, median change: G1: −1.71 G2: −1.00 P < 0.0001 UUI episodes/day, day 7, median change: G1: −1.71 G2: −1.00 P < 0.0001 UUI episodes/day, week 1, median change:* G1: −1.43 G2: −0.86 P < 0.0001 UUI episodes/day, week 4, median change:* G1: −1.71 G2: −1.14 P < 0.0001 UUI episodes/day, week 12, median change:* G1: −1.86 G2: −1.29 P < 0.0001 Urgency severity score, day 1, mean change: G1: 0.00 G2: 0.02 P = 0.47 Urgency severity score, day 2, mean change: G1: −0.08 G2: −0.03 P = 0.13 Urgency severity score, day 3, mean change: G1: −0.11 G2: −0.04 P = 0.015 Urgency severity score, day 4, mean change: G1: −0.12 G2: −0.05 P = 0.031 Urgency severity score, day 5, mean change: G1: −0.13 G2: −0.05 P = 0.021 Urgency severity score, day 6, mean change: G1: −0.08 G2: 0.04 P < 0.0001 Urgency severity score, day 7, mean change: G1: −0.09 G2: 0.03 P < 0.0001 Urgency severity score, week 1, mean change:* G1: −0.09 G2: −0.01 P = 0.0023 Urgency severity score, week 4, mean change:* G1: −0.19 G2: −0.04 P < 0.0001 Urgency severity score, week 12, mean change:* G1: −0.21 G2: −0.02 P < 0.0001 Voids/day, day 1, mean change: G1: −0.66 G2: −0.35 P = 0.14 Voids/day, day 2, mean change: G1: −1.11 G2: −0.75 P = 0.09 Voids/day, day 3, mean change: G1: −1.30 G2: −0.77 P = 0.012 Voids/day, day 4, mean change: G1: −1.33 G2: −0.95 P = 0.086 Voids/day, day 5, mean change:* G1: −1.73 G2: −1.12 P = 0.0037 Voids/day, day 6, mean change:* G1: −1.80 G2: −1.28 P = 0.017 Voids/day, day 7, mean change:* G1: −1.99 G2: −1.44 P = 0.011 Voids/day, week 1, mean change:* G1: −1.42 G2: −0.96 P = 0.0039 Voids/day, week 4, mean change:* G1: −2.34 G2: −1.55 P < 0.0001 Voids/day, week 12, mean change:* G1: −2.67 G2: −1.76 P < 0.0001 Nocturia episodes/day, week 1, median change:* G1: −0.29 G2: −0.29 P = 0.8454 Nocturia episodes/day, week 4, median change:* G1: −0.43 G2: −0.29 P = 0.0299 Nocturia episodes/day, week 12, median change:* G1: −0.57 G2: −0.29 P = 0.0026 Nocturnal urgency severity score, week 1, mean change:* G1: −0.05 G2: 0.03 P = 0.0442 Nocturnal urgency severity score, week 4, mean change:* G1: −0.13 G2: =0.01 P = 0.0062 Nocturnal urgency severity score, week 12, mean change:* G1: −0.17 G2: 0.01 P = 0.0005 OAB-SCS, day 1, median change: G1: −2.50 G2: −0.14 P = 0.014 OAB-SCS, day 2 median change: G1: −3.86 G2: −2.14 P = 0.015 OAB-SCS, day 3, median change: G1: −4.71 G2: −2.71 P = 0.0019 OAB-SCS, day 4, median change: G1: −4.86 G2: −3.36 P = 0.011 OAB-SCS, day 5, median change: G1: −6.43 G2: −3.36 P < 0.0001 OAB-SCS, day 6, median change: G1: −5.43 G2: −2.93 P < 0.0001 OAB-SCS, day 7, median change: G1: −6.29 G2: −3.00 P < 0.0001 OAB-SCS, week 1, median change:* G1: −4.71 G2: −2.29 P < 0.0001 OAB-SCS, week 4, median change:* G1: −8.14 G2: −3.86 P < 0.0001 OAB-SCS, week 12, median change:* G1: −8.43 G2: −4.62 P < 0.0001 Stanford Sleepiness Scale, week 1, mean change:† G1: −0.2 G2: −0.12 Stanford Sleepiness Scale, week 4, mean change:† G1: −0.17 G2: −0.14 Stanford Sleepiness Scale, week 12, mean change:† G1: −0.16 G2: −0.11 Stanford Sleepiness Scale, including T-max time point values only (G1=93, G2=97), week 1, mean change:† G1: −0.42 G2: −0.2 Stanford Sleepiness Scale, including T-max time point values only (G1=144, G2=148), week 4, mean change:† G1: −0.2 G2: −0.19 Stanford Sleepiness Scale, including T-max time point values only (G1=182, G2=179), week 12, mean change:† G1: −0.17 G2: −0.18 Mean Stanford Sleepiness Scale, age group < 65 years, week 1, mean change:† G1: −0.27 G2: −0.19 Mean Stanford Sleepiness Scale, age group < 65 years, week 4, mean change:† G1: −0.14 G2: −0.27 Mean Stanford Sleepiness Scale, age group < 65 years, week 12, mean change:† G1: −0.14 G2: −0.22 Mean Stanford Sleepiness Scale, age group >65 years, week 1, mean change:† G1: −0.04 G2: −0.03 Mean Stanford Sleepiness Scale, age group >65 years, week 4, mean change:† G1: −0.23 G2: 0.03 Mean Stanford Sleepiness Scale, age group >65 years, week 12, mean change:† G1: −0.22 G2: 0.03 Mean Stanford Sleepiness Scale, age group < 75 years, change from baseline to week 1:† G1: −0.21 G2: −0.14 Mean Stanford Sleepiness Scale, age group < 75 years, change from baseline to week 4:† G1: 0.14 G2: −0.16 Mean Stanford Sleepiness Scale, age group < 75 years, week 12, mean change:† G1: 0.15 G2: −0.14 Mean Stanford Sleepiness Scale, age group > 75 years, change from baseline to week 1:† G1: −0.02 G2: 0 Mean Stanford Sleepiness Scale, age group > 75 years, change from baseline to week 4:† G1: −0.49 G2: −0.09 Mean Stanford Sleepiness Scale, age group > 75 years, week 12, mean change:† G1: −0.33 G2: 0.02 Clinically significant increase (≥3 points) from baseline to week 12 in SSS score, n (%):† G1: 5 (1.5) G2: 8 (2.5) Voided volume (mL), week 1, mean change:* G1: 29.23 G2: 6.05 P < 0.0001 Voided volume (mL), week 4, mean change:* G1: 39.50 G2: 9.45 P < 0.0001 Voided volume (mL), week 12, mean change:* G1: 35.59 G2: 9.44 P < 0.0001 Adverse events Any, n (%) G1: 196 (59.6) G2: 153 (46.5) Dry mouth: G1: 65 (19.8) G2: 17 (5.2) Constipation: G1: 36 (10.9) G2: 19 (5.8) Headache not otherwise specified: G1: 18 (5.5) G2: 15 (4.6) UTI not otherwise specified: G1: 16 (4.9) G2: 8 (2.4) Nasopharyngitis: G1: 13 (4.0) G2: 12 (3.6) Cough: G1: 8 (2.4) G2: 1 (0.3) Diarrhea: G1: 7 (2.1) G2: 13 (4.0) AEs leading to treatment discontinuation, %: G1: 7.3 G2: 4.6 Most common AEs leading to discontinuation: Constipation: G1: 1.8% G2: 0.6% Dry mouth: G1: 1.5% G2: 0.0% At least one CNS event: G1: 5.8% G2: 5.2% Somnolence G1: 0.3% G2: 0.6% Sedation: G1: 0 G2: 0.3% | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: − Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: + Length of followup: + Measurement methods: + Measurement reliability: − Intervention description: +
Author: Salvatore et al., 2005 Country and setting: UK, Urogynecology specialty Enrollment period: 1 year with phone questionnaire at 2 years Funding: NR Author industry relationship disclosures: NR | Design: Prospective randomized phone questionnaire Intervention: Oxybutynin with incremental increase in dosage to 5mg t.i.d. over 6 weeks at 14 day intervals Groups: G1: Oxybutynin 2.5 mg b.i.d. G2: Oxybutynin 5 mg at night N at enrollment: G1: 42 G2: 44 N at follow-up: G1: 27 G2: 39 Women, %: 100 Age, yrs ± SD: G1: 59.2 ± 12.6 G2: 53.3 ± 14.4 Race/ethnicity: NR | Inclusion criteria: • Women • Video-urodynamic diagnosis of DO or low bladder capacity • DO- ≥ 1 contractions on filling cystometry associated with urgency • Low bladder compliance = linear detrusor pressure rise during filling cystometry > 15 cmH2O at 500mL associated with urgency or leakage • Exclusion criteria: NR | Stopped treatment, n (%) G1: 16 (59.3) G2: 28 (71.8) | SUI episdes/day, mean ± SD: G1: 0.85 ± 0.78 G2: 1.27 ± 1.17 P = 0.04 Nocturia episodes/ day, mean ± SD: G1: 1.21 ± 1.17 G2: 2.04 ± 1.45 P = 0.01 Oxybutynin compliance, 2 yrs, n (%) : G1: 11 (40.7) G2: 11 (28.2) Time on drug, n: 1 month: G1: 6 G2: 12 1–2 months: G1: 6 G2: 11 1–2 months: G1: 2 G2: 3 3–4 months: G1: 2 G2: 2 Duration of treatment: G1: NR G2: NR P = 0.08 General perception of improvement: P = 0.58 Max dose of oxybutynin reached: P = 0.31 Present dose of oxybutynin: P = 0.45 Present overall severity of symptom: P = 0.12 Daytime frequency: P = 0.78 Urgency: P = 0.78 Urge incontinence: P = 0.18 Pad usage: P = 0.24 Side effects, n: G1: 3 G2: 4 Dry Mouth, n: G1: 1 G2: 4 Dry Throat, n: G1: 2 G2: 0 Dry nose, n: G1: 0 G2: 1 Dry eyes, n: G1: 0 G2: 1 Nausea, n: G1: 0 G2: 4 Tachycardia, n: G1: 0 G2: 1 Dizziness, n: G1: 0 G2: 2 Constipation, n: G1: 0 G2: 0 Headache. N: G1: 0 G2: 1 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: − Masking: NA Pt selection criteria: − Loss to followup: − Drop-out rates: NR Power calculation: + Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: NR Baseline characteristics: − Length of followup: ++ Measurement methods: + Measurement reliability: − Intervention description: +
Author: Salvatore et al., 2007 Country and setting: Italy, Urogynecology outpatient clinic Enrollment period: January 2004 to October 2005 Funding: NR Author industry relationship disclosures: NR | Design: Cohort Intervention: Tolterodine SR 4 mg qd Groups: G1: vaginal profile stage 0a or Ia G2: anterior prolapse ≥ stage IIa N at enrollment: G1: 184 G2: 51 N at follow-up: NR Women, %: 100 Age, median (range): G1: 59 (20, 85) G2: 59 (35, 82) Race/ethnicity: NR Parity, mean (range): G1: 2 (0–6) G2: 2 (0–6) Menopausal, n (%): G1: 132 (72) G2: 7 (18) | Inclusion criteria: • Women • Urodynamically proven OAB who had no prolapse or pure anterior vaginal prolapse • Proven detrusor overactivity Exclusion criteria: • All symptoms or signs related to voiding difficulties • Prolapse | Previous surgery, n (%): G1: 52 (28) G2: 11 (22) HRT, n (%) G1: 35 (26) G2: 7 (18) | Improvement in condition or cured, n (%): G1: 158 (85.9) G2: 31 (60.8)* P = 0.0002 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: NR Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: poor Age: + Baseline OAB status: NR Baseline characteristics: − Length of followup: + Measurement methods: − Measurement reliability: − Intervention description: +
Author: Salvatore et al., 2008 Country and setting: Italy, academic health center Enrollment period: January 2005 to August 2005 Funding: NR Author industry relationship disclosures: None | Design: prospective cohort Intervention: tolterodine ER 4 mg qd for 12 wks Groups: G1: Involuntary detrusor contractions during filling G2: Involuntary detrusor contractions after p N at enrollment: 111 N at follow-up: 109 G1: 84 G2: 25 Age, mean yrs: G1: 54.5 G2: 52 BMI G1: 25.5 (19–36) G2: 25 (18–38) | Inclusion criteria: • UDS+ detrusor overactivity Exclusion criteria: • UTI • DM • neurological dz • genital prolapse >/= POP-Q stage II • previous anti-incontinence or prolapse surgery • previous trt w/antimuscarinics Indications, N: | Menopause, n(%) G1: 53 (63) G2: 16 (64) HRT, n(%) G1: 13 (24.5) G2: 6 (37.5) Reported in relation to urodynamic findings 1. women who experienced involuntary detrusor contractions during the filling phase spontaneously N=84 2. women who experienced involuntary detrusor contractions after provocative maneuvers such as listening to running water or washing hands in cold water N=25 | Non-response to trt, proportion (%): G1: 12/84 (14) G2: 12/25 (48) G1<G2 (P = 0.0008) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: - Masking: - Pt selection criteria: - Loss to followup: ++ Drop-out rates: ++ Power calculation: - Statistical issues: - EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: - Intervention description: +
Author: Sand et al., 2004 Country and setting: US, Specialty clinic Enrollment period: Subanalysis of OBJECT trial, women only Funding: ALZA Corp Author industry relationship disclosures: NR | Design: RCT Intervention: 10mg ER Oxybutynin daily vs 4mg Tolterodine (2mg b.i.d.) Groups: G1: 10mg ER Oxybutynin daily x 12 wks G2: 4mg Tolterodine (2mg b.i.d.) x 12 wks Stratified by age: a: Age ≤ 64 b: Age 65–74 c: Age ≥ 75 N at enrollment: G1: 152 G2: 163 N at follow-up: G1: 132 G2: 146 Women, %: 100 Age, yrs ± SD: G1: 58.4 G2: 58.8 Race/ethnicity: NR | Inclusion criteria: • ≥ 7 and ≤ 50 UUI episodes/week • ≥ 10 voids/day • MUI included if predominant UUI Exclusion criteria: • UTI • IC • Urethral diverticulum • Bladder tumor • Bladder stone • Delivery within 6 mos • Pelvic, bladder, vaginal surgery in ≤ 6 mos • PVR ≥ 150 mL • Cardiovascular, renal, pulmonary, gastrointestinal, endocrine, neurologic, autoimmune, hematological, urological, psychiatric, or hepatic disease • Hematuria • Positive urine culture • Narrow angle glaucoma • Obstructive uropathy • Myasthenia gravis • POP to hymenal ring • Gastrointestinal obstruction • Decreased GI motility • GI narrowing • GI retention • Investigational drugs within 1 month of screening • Hypersensitivity to drugs • Current drug/EtOH abuse • Pregnant • Breastfeeding • Inability to follow protocol | UUI episodes/week, mean: G1: 25.2 G2: 25.1 Incontinence episodes/week, mean: G1: 28.1 G2: 28.9 Voids/week, mean: G1: 91.7 G2: 91.6 Naïve to anti-cholinergics, %: G1: 60.5 G2: 60.7 | UUI episodes/week, %: G1: 6.2 G2: 8.5 G1a: 5.0 G2a: 8.4 G1b: 5.5 G2b: 7.5 G1c: 8.5 G2c: 11.1 G1/G2: P = 0.038 G1a/G2a: P = 0.005 G1b/G2b: P = 0.337 G1c/G2c: P = 0.568 Incontinence episodes/week, mean: G1: 7.3 G2: 10.1 G1a: 5.8 G2a: 10.0 G1b: 6.1 G2b: 9.2 G1c: 10.5 G2c: 12.5 G1/G2: P = 0.030 G1a/G2a: P = 0.005 G1b/G2b: P = 0.164 G1c/G2c: P = 0.714 Voids/week, mean: G1: 68.0 G2: 71.2 G1a: 63.7 G2a: 71.2 G1b: 73.8 G2b: 71.9 G1c: 66.8 G2c: 65.5 G1/G2: P = 0.272 G1a/G2a: P = 0.024 G1b/G2b: P = 0.706 G1c/G2c: P = 0.838 Dry mouth, %: G1: 28.3 G2: 33.7 Constipation, %: G1: 8.6 G2: 6.7 Retention, %: G1: 4.0 G2: 1.2 Blurred vision, %: G1: 2.6 G2: 0.6 Dizziness, %: G1: 3.9 G2: 4.3 Insomnia, %: G1: 0.7 G2: 1.8 Somnolence, %: G1: 3.3 G2: 1.8 Nervousness, %: G1: 0 G2: 1.2 Headache, %: G1: 9.2 G2: 10.4 Dyspepsia, %: G1: 5.3 G2: 6.1 Nausea, %: G1: 3.3 G2: 1.8 Vomiting, %: G1: 2.0 G2: 1.8 | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: - Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Sand et al., 2006 [See evidence table for Sand et al., 2007] Country and setting: US, 327 centers Enrollment period: NR Funding: Watson Laboratories, Inc Author industry relationship disclosures: NR | Design: RCT Intervention: Oxybutynin transdermal system 3.9 mg/day, twice weekly patch for up to 6 months with “standard instruction” or with “educational intervention”. Evaluate changes in HRQoL using Kings Health Questionnaire (KHQ) and Beck Depression Inventory II (BDI-II) Groups: G1: Standard instructions G2: Educational intervention (educational booklet, OAB newsletters, dosing reminders, calendar reminders, bladder diary) N at enrollment: Total: 2878 G1: G2:1596 N at follow-up: NR Age, mean yrs ± SD: 62.5 ± 14.8 Women, %: 87.2 Race/ethnicity, %: White: 83.6 African American: 9.9 Hispanic: 4.8 Asian: 1.2 Other: 0.5 Follow-up: 6 months | Inclusion criteria: • ≥18 years old • UUI, urinary urgency or frequency • Willing to discontinue all prescription and OTC medications for OAB • Capable of completing QOL questionnaires without assistance • Negative pregnancy test & medically acceptable contraceptive Exclusion criteria: • Contra-indications to oxybutynin • Reversible etiologies for OAB • Prior treatment with Oxytrol • Long-term care facilities and nursing homes | History of OAB, years, %: <1 yr: 12.0% 1–2 yr: 18.5% 2–4 yr: 23.1% ≥ 4 yr: 46.4% Sexually active: Yes: 1500 (59.2%) No: 1034 (40.8%) Coital incontinence, n (%): Omitted or NA: 1924 (77.2) A little: 324 (13) Moderately: 137 (5.5) A lot: 108 (4.3) Total with incontinence: 569 (22.8%) KHQ, embarrassed by bladder problems: Yes: (1845/2571) 71.8% OAB affects sex life: 586 (39% of 1500 who answered; 23.1% of total population) OAB affects relationship with partner: Yes: 622 (37.3% of 1666 who answered, 24.4% of total population) Decreased interest in sex: Total: 1219 (52.1%) Less interest: 589 (25.2%) Much less interest: 228 (9.7%) Complete loss of interest: 402 (17.2%) | Coital incontinence, n (%): Omitted or NA: 1831 (80.7) A little: 260 (11.5) Moderately: 116 (5.1) A lot: 62 (2.7) Total with incontinence: 438 (19.3%) Coital incontinence, n (%): Improved: 277 (12.6%) Worsened: 165 (7.5%) P < 0.0001 Embarrassed by OAB: Improved: 828 (35.5%) Worsened: 251 (11.1%) P < 0.0001 Effect of OAB on sex life: Improved: 429 (19.1%) Worsened 251 (11.1%) P < 0.0001 Effect of OAB on relationship with partners: Improved: 444 (19.6%) Worsened: 271 (11.9%) P < 0.0001 Interest in sex: Improved: 472 (23.4%) Worsented: 246 (12.2%) P < 0.0001 Improvement in all KHQ domains and BDI-II summary scores (P < 0.0001) No difference between G1 and G2 in baseline sexual symptoms or improvement | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: - Pt selection criteria: + Loss to followup: + Drop-out rates: - Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Sand et al., 2007 Country and setting: US, Multicenter, 327 sites (141 Urology 141, 96 Primary care, 43 Ob-Gyn, 17 Geriatric Med) Enrollment period: NR Funding: Watson Laboratiories, Inc Author industry relationship disclosures: 7 of 7 Allergan (1) Astellas (1) Esprit (1) GlaxoSmithKline (2) GSK (1) GTx (1) Indevus-Esprit (1) Lilly (1) Novartis (3) Ortho-McNeil (1) Ortho Urology (1) Pfizer (4) Sanofi (1) USB (1) Watson (6) | Design: RCT, open-label (case series for drug, RCT for educational materials) Intervention: Oxybutynin transdermal system 3.9 mg/day, twice weekly patch for up to 6 months with “standard instruction” or with “educational intervention”. Evaluate changes in HRQoL using KHQ Groups: G1: Standard instructions G2: Educational intervention (educational booklet, OAB newsletters, dosing reminders, calendar reminders, bladder diary) N at enrollment: Total: 2,878 G1: 1,282 G2: 1,596 Women, %: 87.2 Age, yrs ± SD: 62.5 ± 14.8 Race/ethnicity, %: White: 83.6 African American: 9.9 Hispanic: 4.8 Asian: 1.2 Other: 0.5 Follow-up: 6 months | Inclusion criteria: • Age ≥18 • UUI, urinary urgency or frequency • Willing to discontinue all prescription and OTC medications for OAB • Capable of completing QOL questionnaires without assistance • Negative pregnancy test & medically acceptable contraceptive Exclusion criteria: • Contraindications to oxybutynin • Reversible etiologies for OAB • Prior treatment with Oxytrol • Long-term care facilities and nursing homes | KHQ, UUI severity item score, %: A lot: 38.1 Moderately: 31.3 A little: 20.5 Omitted, N/A: 10.1 KHQ, urgency severity item score, %: A lot: 49.2 Moderately: 30.3 A little: 14.8 Omitted, N/A: 5.6 KHQ, frequency severity item score, %: A lot: 59.3 Moderately: 32.5 A little: 7.2 Omitted, N/A:1.0 KHQ, nocturia severity item score, %: A lot: 47.3 Moderately: 33.5 A little: 16.7 Omitted, N/A: 2.4 History of OAB, years, %: <1 year: 12.0 1–2 years: 18.5 2–4 years: 23.1 ≥ 4 years: 46.4 OAB Severity: No problem: 1.8 Very minor: 4.6 Minor: 15.5 Moderate: 33.0 Severe: 28.4 Many severe problems: 16.7 Previous OAB treatments, n (%): 0: 43.4 1: 38.7 2: 13.1 3: 2.9 4: 1.9 KHQ, general health perception, mean ± SD: 28.2 ± 19.8 KHQ, incontinence Impact, mean ± SD: 69.3 ± 27.4 KHQ, symptom severity, mean ± SD: 55.9 ± 20.5* KHQ, role limitations, mean ± SD: 45.1 ± 31.0 KHQ, physical limitations, mean ± SD: 46.7 ± 31.6 KHQ, social limitations, mean ± SD: 25.6 ± 28.3 KHQ, emotions, mean ± SD: 30.0 ± 29.2 KHQ, personal relationships, mean ± SD: 20.6 ± 29.5*** KHQ, sleep/energy, mean ± SD: 54.2 ± 27.3 KHQ, severity (coping) measures, mean ± SD: 47.9 ± 26.4 | KHQ, UUI severity item score, %: A lot: 21.3 Moderately: 29.5 A little: 31.6 Omitted, N/A: 17.7 KHQ, urgency severity item score, %: A lot: 27.3 Moderately: 33.8 A little: 27.3 Omitted, N/A: 11.5 KHQ, frequency severity item score, %: A lot: 33.5 Moderately: 45.2 A little: 18.7 Omitted, N/A: 2.6 KHQ, nocturia severity item score, %: A lot: 27.5 Moderately: 35.4 A little: 31.3 Omitted, N/A: 5.7 KHQ, general health perception, mean ± SD (% improvement): −1.2 ± 17.4 (−4.3) KHQ, incontinence Impact, mean ± SD (% improvement): −13.5 ± 29.5 (−19.5) KHQ, symptom severity, mean ± SD (% improvement): −12.4 ± 24.8 (−22.2)*** KHQ, role limitations, mean ± SD (% improvement): −13.3 ± 29.2 (−29.5) KHQ, physical limitations, mean ± SD (% improvement): −11.7 ± 29.9 (−25.1) KHQ, social limitations, mean ± SD (% improvement): −6.7 ± 23.7 (−26.2) KHQ, emotions, mean ± SD (% improvement): −8.8 ± 25.4 (−29.3) KHQ, personal relationships, mean ± SD (% improvement): −6.0 ± 23.5 (−29.1)*** KHQ, sleep/energy, mean ± SD (% improvement): −11.2 ± 24.1 (−20.7) KHQ, severity (coping) measures, mean ± SD (% improvement): −8.6 ± 21.3 (−18.0) Side effects, application site, %: Total: 14.0 Pruritis: 4.9 Erythema: 4.6 Dermatitis: 4.4 Irritation: 3.2 Other: 2.0 Side effects, %: Rash: 3.0 Dry mouth: 2.6 Pruritis: 2.6 Skin irritation: 2.1 Withdrew due to AEs, %: 21.3 Withdrew: 1452 (50.5%) Adverse events 21.3% Withdrawn consent: 7.5% Requirement for alternative therapy 7.4% Loss to follow-up 7.2% Noncompliance 5.6% Administrative decision 0.7% Ineligible: 0.4% Death 0.1% No reason given 0.3% | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: NA Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Song et al., 2006 Country and setting: Korea, Medical Center Enrollment period: May 2001 to April 2002 Funding: NR Author industry relationship disclosures: NR | Design: RCT Intervention: bladder training (BT) vs. Tolterodine vs. BT + Tolterodine Groups: G1: BT x 12 wks G2: Tolterodine 2 mg b.i.d. x 12 wks G3:Tolterodine 2 mg b.i.d. + BT x 12 wks N at enrollment: G1: 46 G2: 47 G3: 46 N at follow-up: G1: 26 G2: 32 G3: 31 Women, %: 100 Age, mean ± SD: G1: 45.73 ± 12.68 G2: 48.41 ± 9.38 G3: 45.42 ± 9.54 Race/ethnicity, %: Korean: 100 | Inclusion criteria: • Age ≥ 18 • ≥ 8 voids/day • Urge with or without incontinence • Symptom duration ≥ 3 months • No prior history of treatment for OAB Exclusion criteria: • Active urinary tract infection • Clinically significant SUI • Bladder outlet obstruction • Interstitial cystitis • Glaucoma • Megacolon • Maximal urine flow rate of < 10 mL/sec • Postvoid residual volume > 30% of the total amount voided on uroflowmetry | Voids/day, mean ± SD: G1: 10.93 ± 2.14 G2: 11.63 ± 2.57 G3: 11.90 ± 1.51 Nocturia episodes/day, mean ± SD: G1: 1.45 ± 1.14 G2: 1.72 ± 1.04 G3: 1.96 ± 1.49 Urgency, mean score ± SD: G1: 2.58 ± 1.30 G2: 2.81 ± 0.74 G3: 3.00 ± 1.10 Maximum flow rate (mL/s), mean ± SD: G1: 20.35 ± 8.44 G2: 22.56 ± 4.94 G3: 21.19 ± 4.96 Residual urine (mL), mean ± SD: G1: 9.08 ± 22.56 G2: 7.59 ± 12.39 G3: 6.42 ± 10.16 Symptom duration (years), mean ± SD: G1: 6.44 ± 6.84 G2: 4.54 ± 5.15 G3: 4.10 ± 3.99 | Voids/day, mean (% decrease) G1: 8.1 (25.9%)* G2: 8.1 (30.2%)* G3: 7.9 (33.5%)* G3/G1: P < 0.05 Nocturia episodes/day, mean (% reduction): G1: 0.6 (56.1%)* G2: 0.6 (65.4%)* G3: 0.6 (66.3%)* Urgency, mean score (% reduction): G1: 1.4 (44.8%)* G2: 1.1 (62.2%)* G3: 1.2 (60.2%)* G3/G1: P = 0.021 G2/G1: P = 0.017 G2/G3: P = NS Satisfaction, mean score (% improved): G1: 1.5 (53.9) G2: 1.4 (63.0) G3: 1.3 (71.0) Dry mouth, n (%): G1: 0 (0.0) G2: 7 (21.9) G3: 9 (28.9) Hesitancy, n (%) G1: 0 (0.0) G2: 3 (9.4) G3: 2 (6.5) Decreased appetite/constipation, n (%): G1: 0 (0.0) G2: 2 (6.3) G3: 2 (6.5) Headache, n (%): G1: 0 (0.0) G2: 1 (3.1) G3: 0 (0.0) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: − Pt selection criteria: + Loss to followup: − Drop-out rates: + Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Staskin et al., 2007 Country and setting: US, Multicenter Enrollment period: August 2005 to May 2006 Funding: Esprit Pharma, Indevus Pharmaceuticals Author industry relationship disclosures: 4 of 4 Allergan (3) Astellas (3) Eli Lilly (1) Esprit (4) GlaxoSmithKline (2) Indevus (3) Medtronics (1) Novartis (3) Ortho (1) Pfizer (2) Schwartz (1) Watson (4) | Design: RCT Intervention: Trospium chloride ER Groups: G1: trospium chloride ER 60mg qd G2: placebo N at enrollment: G1: 298 G2: 303 N at follow-up: G1: 263 G2: 273 Women, n (%): G1: 254 (85.2) G2: 256 (84.5) Age, mean (SE): G1: 59.6 (0.77) G2: 59.3 (0.70) Race/ethnicity, %: White: G1: 86.6 G2: 85.5 Black: G1: 8.7 G2: 9.9 Hispanic: G1: 3.0 G2: 2.3 Asian: G1: 1.0 G2: 1.3 Other G1: 0.7 G2: 1.0 | Inclusion criteria: • Age ≥18 • OAB symptoms for ≥ 6 mos • ≥ 1 “severe” urgency severity rating per 3 days, measured Indevus Urgency Severity Scale • ≥ 30 voids per 3 days • ≥ 1 UUI episodes/day • Average total volume voided < 3L per day and < 250 per void Exclusion criteria: • SUI • Insensate incontinence or overflow incontinence • Neurogenic bladder • Significant renal disease • Hematuria • Current UTI • ≥ 3 UTIs during previous year • Significant bladder outlet obstruction • Indwelling catheter • Active IBD • Interstitial cystitis • Bladder cancer • PSA > 4 ng/ml • Prostate cancer or chronic prostatitis • Undergoing or likely to undergo bladder retraining or drill program • Diuretic estrogen use outside of a long-term stable program • | Prior OAB medications, n (%): G1: 159 (53.4) G2: 151 (49.8) | UUI episodes/day, wk 1, mean change ± SD: G1: −1.86 ± 0.13 G2: −1.24 ± 0.14 P = .0003 UUI episodes/day, wk 4, mean change ± SD: G1: −2.36 ± 0.17 G2: −1.75 ± 0.15 P = 0.0051 UUI episodes/day, wk 12, mean change ± SD: G1: −2.48 ± 0.17 G2: −1.93 ± 0.16 P = 0.0022 UUI episodes/wk, wk 1, mean change ± SD: G1: −13.03 ± 0.91 G2: −8.66 ± 0.95 P = 0.0003 UUI episodes/wk, wk 4, mean change ± SD: G1: −16.50 ± 1.17 G2: −12.24 ± 1.07 P = 0.0054 UUI episodes/wk, wk 12, mean change ± SD: G1: −17.34 ± 1.18 G2: −13.49 ± 1.09 P = 0.0024 Urgency-associated voids/day, wk 1, mean change ± SD: G1: −1.90 ± 0.16 G2: −1.34 ± 0.16 P = 0.0033 Urgency-associated voids/day, wk 4, mean change ± SD: G1: −2.66 ± 0.17 G2: −1.71 ± 0.18 P = 0.0003 Urgency-associated voids/day, wk 12, mean change ± SD: G1: −3.11 ± 0.17 G2: −2.12 ± 0.19 P < 0.0001 Voids/day, wk 1, mean change ± SD: G1: −1.66 ± 0.14 G2: −1.24 ± 0.13 P = 0.0092 Voids/day, wk 4, mean change ± SD: G1: −2.44 ± 0.15 G2: −1.58 ± 0.15 P < 0.001 Voids/day, wk 12, mean change ± SD: G1: −2.81 ± 0.15 G2: −1.99 ± 0.16 P < 0.001 Urgency severity score/void, wk 1, mean change ± SD: G1: −0.21 ± 0.02 G2: −0.10 ± 0.02 P = 0.0002 Urgency severity score/void, wk 4, mean change ± SD: G1: −0.26 ± 0.03 G2: −0.13 ± 0.03 P = 0.0008 Urgency severity score/void, wk 12, mean change ± SD: G1: −0.32 ± 0.03 G2: −0.18 ± 0.03 P = 0.0004 OAB-SCS, wk 1, mean change ± SD: G1: −6.96 ± 0.51 G2: −4.81 ± 0.55 P = 0.0002 OAB-SCS, wk 4, mean change ± SD: G1: −9.67 ± 0.56 G2: −6.13 ± 0.64 P < 0.0001 OAB-SCS, wk 12, mean change ± SD: G1: −11.20 ± 0.55 G2: −7.80 ± 0.67 P < 0.0001 Voided volume (mL), wk 1, mean change ± SD: G1: 21.61 ± 2.76 G2: 12.07 ± 2.11 P = 0.0036 Voided volume (mL), wk 4, mean change ± SD: G1: 30.00 ± 3.14 G2: 17.24 ± 2.47 P = 0.0007 Voided volume (mL), wk 12, mean change ± SD: G1: 29.77 ± 3.16 G2: 18.89 ± 2.79 P = 0.0039 Subjects who achieved normalization, %: G1: 20.5 G2: 11.3 P < 0.01 At least 1 treatment emergent AE, n (%): G1: 80 (26.8) G2: 53 (17.5) Dry mouth, n (%): G1: 26 (8.7) G2: 9 (3.0) Constipation, n (%): G1: 28 (9.4) G2: 4 (1.3) Headache, n (%): G1: 3 (1.0) G2: 8 (2.6) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: − Loss to followup: + Drop−out rates: + Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Steers et al., 2005 Country and setting: US (49) and Canada (15), Multicenter Enrollment period: NR Funding: Pfizer Author industry relationship disclosures: 3 of 4 Pfizer (3) | Design: RCT Intervention: Darifenacin CR vs. placebo Groups: G1: Darifenacin CR 7.5–15 mg qd G2: Placebo G3: Increased dose at 2 wks G4: No increased dose at 2 wks N at enrollment: G1: 269 G2: 129 N at follow-up: G1: 261 G2: 123 Women, N (%): G1: 227 (84.7) G2: 106 (83.5) Age, yrs (range): G1: 57.5 (27–89) G2: 58.5 (22–86) Aged < 65 years, n (%) G1: 183 (68.3) G2: 81 (63.8) Race/ethnicity: NR | Inclusion criteria: • Age ≥ 18 • OAB symptoms for ≥ 6 mos • Capable of independent toileting • ≥ 5 episodes of UI per wk • ≥ 8 voids/day • Strong desire to void ≥ 1 times per day • Adequate method of contraception Exclusion criteria: • BPH on a non-stable dose of finasteride for < 6mos • Contra-indications to anticholinergic medication • Clinically significant SUI • BOO • PVR of > 200 mL • Pregnant or breastfeeding • GU conditions that could cause urinary symptoms • Fecal impaction or severe constipation (< 3 BM/wk) • Urogenital surgery in past 6 mos • Bladder biopsy in last 30 days • Indwelling catheter • Intermittent self-catherization • Intention to start a bladder-training program during study • Concomitant use anticholinergics, antispasmodics, opioids, other drugs known to cause constipation, HRT (unless taken for ≥ 2 months), and P450 3A4 inhibitors | Urgency episodes/day, median (IQR): G1: 8.3 (6.4, 10.6) G2: 8.0 (5.6, 10.3) Severity of urgency, VAS score, median (IQR): G1: 53 (41–66) G2: 53 (39–66) Incontinence episodes/wk, median (IQR): G1: 16.3 (9.1, 29.6) G2: 14.0 (9.0, 26.0) Significant leaks/week, median (IQR): G1: 7.0 (2.0, 13.1) G2: 5.3 (1.0, 11.2) Voids/day, median (IQR): G1: 9.9 (8.6, 11.9) G2: 10.4 (8.3, 11.6) Nocturia episodes/week, median (IQR): G1: 12.0 (7.0–16) G2: 11.2 (6.1–16) Voided volume (mL), median (IQR): G1: 175 (125, 253) G2: 177 (120, 229) Idiopathic OAB, n (%): G1: 253 (94.4) G2: 123 (96.8) Previous drug therapy for frequency, enuresis, or incontinence, n (%): G1: 62 (23.1) G2: 32 (25.2) | Urgency episodes/day, median change (%): G1: −2.3 (−28.2) G2: −0.9 (−11.0) G1/G2: P < 0.001 Severity of urgency, VAS score, median change (%): G1: −9.1 (−16.8) G2: −3.2 (−5.6) G1/G2: P < 0.05 Significant leaks/week, median change (%): G1: −3.0 (−67.3) G2: −1.8 (−42.9) G1/G2: P < 0.01 Voids/day, median change (%): G1: −1.9 (−18.9) G2: −1.0 (−10.0) G1/G2: P < 0.001 Nocturia episodes/week, median change (%): G1: −2.0 (−18.0) G2: −1.0 (−12.5) G1/G2: P = NS Voided volume (mL), median change (%): G1: 19 (10.5) G2: 7 (5.4) G1/G2: P < 0.05 Constipation, n (%): G3: 24 (22.2) G4: 32 (20.0) Dry Mouth, n (%): G3: 22 (20.4) G4: 28 (17.5) Headache, n (%): G3: 5 (4.6) G4: 13 (8.1) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: + Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Steers et al., 2007 Country and setting: Australia, Canada, US; multicenter, 30 centers Enrollment period: July 2001 to September 2003 Funding: Eli Lilly, Boehringer Ingelheim GmbH. Author industry relationship disclosures: 7 of 7 Eli Lilly (7) | Design: RCT, placebo-controlled, double-blind, stratified by urodynamic observation Intervention: duloxetine vs placebo Groups: G1: placebo × 2 wks, duloxetine 40 mg b.i.d. × 4 wks, duloxetine 60 mg b.i.d. × 8 wks G2: placebo b.i.d. × 14 wks N at enrollment: G1: 153 G2: 153 N at follow-up, N (%): G1: 90 (59) G2: 120 (78) Age, mean ± SD: G1: 56.0 ± 14.8 G2: 53.3 ± 14.1 Women, N (%): 306 (100) BMI, mean kg/m2 ± SD: G1: 29.2 (7.4) G2: 30.2 (7.8) | Inclusion criteria: • women • >18 yoa • predominant symptoms of OAB ≥ 3 months defined as bothersome urinary urgency and/or urge, abnormal voiding frequency (≤2 h mean daytime voiding interval) • UDS observation of either detrusor OA or urgency that limited bladder capacity to <400mL Exclusion criteria: • −SUI • PVR >100 mL • Mean 24 h total volume voided of ≥ 3L • Urine culture • ≥4 UTIs in past yr • Regular use of meds for OAB w/in 4wks of enrollment • Previous use of duloxetine • Continence surgery ≤ 6 mos • Any major surgery ≤ 3 mos • Pelvic organ prolapse > ICS Stage II • Non-pharm intervention ≤ 3 mos • Pelvic-floor-muscle training that had not been stable for 3 mos or would not remain stable during the trial | Incontinence episodes, all assessable pts, mean: G1: 1.70 G2: 1.44 Urinary incontinence episode (wet OAB): G1: 2.34 G2: 2.07 Pads/week, mean: G1: 7.81 G2: 7.05 Voids/day, mean: G1: 10.76 G2: 10.49 Daytime voiding interval, mean: G1: 113.58 G2: 119.63 Nocturia episodes/day, mean: G1: 1.47 G2: 1.63 Voided volume (mL), mean: G1: 175.41 G2: 183.40 QoL Instrument score, mean ± SD: I-QOL: G1: 56.65 ± 24.80 G2: 57.11 ± 23.3 U-IIQ: G1: 2.44 ± 1.18 G2: 2.39 ± 1.15 U-UDI: G1: 3.18 ± 0.58 G2: 3.15 ± 0.71 Bladder compliance (mL/cmH_2_0) G1: 71.8 ± 85.7 G2: 79.3 ± 91.0 SUI: G1: 0 G2: 0 Maximum cystometric capacity mL G1: 318.3 ± 152.4 G2: 330.4 ± 135.4 Volume threshold for first detrusor contraction mL G1: 226.4 ± 141.8 G2: 250.6 ± 146.0 Moderate or severe bladder condition from PGI-I Scale (%): G1: 84.9 G2: 88.8 I-QOL total score, mean ± SD: G1: 56.6 (24.9) G2: 57.0 (23.2) UIE, mean ± SD: G1: 1.55 (2.08) G2: 1.41 (2.00) VE24, mean ± SD: G1: 10.8 (3.3) G2: 10.6 (3.6) Symptom of bothersome urgency, %: G1: 99.3 G2: 99.3 Symptoms of urge UI, %: G1: 88.2 G2: 88.9 Symptoms of SUI: G1: 42.5 G2: 50.3 Urodynamic DOA G1: 42.5 G2: 41.8 Sensory urgency: G1: 57.5 G2: 58.2 Previous continence surgery, %: G1: 13.1 G2: 11.8 Current pelvic-floor muscle training, %: G1: 9.2 G2: 11.8 Previous behavioral therapy, %: G1: 3.3 G2: 2.6 Previous tolterodine therapy, %: G1: 10.5 G2: 7.2 Previous oxybutynin therapy, %: G1: 13.0 G2: 9.2 | Incontinence episodes, all assessable pts, mean change: G1: −0.74 G2: −0.14 P = 0.006 Incontinuence episodes, wet OAB pts, mean change: G1: −1.03 G2: −0.24 P = 0.032 Pads/week, mean change: G1: −1.41 G2: −0.53 P = 0.143 Voids/day, mean change: G1: −1.81 G2: −0.62 P < 0.001 Daytime voiding interval, mean change: G1: 29.46 G2: 6.51 P < 0.001 Nocturia episodes/day, mean change: G1: 0.05 G2: −0.18 P = 0.004 Voided volume (mL), mean change: G1: 8.85 G2: 5.07 P = 0.171 Condition improved, 80 mg/day, %: G1: 59.9 G2: 42.9 P = 0.005 Condition improved, 120 mg/day, %: G1: 61.6 G2: 42.1 P = 0.008 Condition improved, overall, %: G1: 53.4 G2: 41.9 P = 0.052 Headache: G1: 13 (8.5) G2: 8 (5.2) P = 0.336 Diarrhea: G1: 10 (6.5) G2: 5 (3.3) P = 0.289 Cough: G1: 7 (4.6) G2: 6 (3.9) p>0.999 Change in QOL Instrument score, mean ±: I-QOL G1: 8.37 ± 15.89 G2: 4.87 ± 15.27 G1>G2 (P = .035) U-IIQ G1: −0.44 ± 0.76 G2: −0.22 ± 0.87 P = 0.018 U-UDI G1: −0.26± 0.67 G2: −0.19 ± 0.59 P = 0.440 Bladder compliance (mL/cmH20) G1: 16.5 ±131.3 G2: 1.0 ± 120.8 P = 0.655 Maximum cystometric capacity mL G1: 22.1 ± 116.4 G2: 23.8 ± 108.5 P = 0.619 Volume threshold for first detrusor contraction mL G1: 90.0 ± 200.6 G2: 13.9 ± 112.8 P = 0.254 PGI-I score Better 4 wks (80 mg/day) G1: 59.9 G2: 42.9 P = 0.005 TEAEs reported, % G1: 79.1 G2: 55.6 P < 0.001 Appetite decreased G1: 6 (3.9) G2: 0 G1>G2, P = 0.030 Arthralgia G1: 6 (3.9) G2: 3 (2.0) P = 0.501 Somnolence: G1: 6 (3.9) G2: 0 P = 0.30 Sweating increased: G1: 6 (3.9) G2: 2 (1.3) P = 0.283 UTI: G1: 6 (3.9) G2: 6 (3.9) p>0.999 Anorgasmia G1: 5 (3.3) G2: 0 G1>G2, P = 0.060 Anxiety: G1: 5 (3.3) G2: 0 G1>G2, P = 0.060 Tremor: G1: 5 (3.3) G2: 0 G1>G2, P = 0.060 Upper respiratory infection: G1: 5 (3.3) G2: 4 (2.6) P > 0.999 Vomiting: G1: 5 (3.3) G2: 3 (2.0) P = 0.723 Abdominal pain: G1: 4 (2.6) G2: 1 (0.7) P = 0.371 Back pain: G1: 4 (2.6) G2: 1 (0.7) P = 0.371 Note: mean change consistent at 4 wks (duloxetine 80 mg/d) and 8 wks (duloxetine 120 mg/d) Change in I-QOL total score, mean ± SD: Discontinuation due to TEAEs, % G1: 28.1 G2: 5.2 P < 0.001 Treatment emergent adverse events, n (%): Nausea: G1: 47 (30.7) G2: 7 (4.6) G1>G2, P < 0.001 Dry mouth: G1: 25 (16.3) G2: 2 (1.3) G1>G2, P < 0.001 Dizziness: G1: 22 (14.4) G2: 1 (0.07) G1>G2, P < 0.001 Constipation: G1: 21 (13.7) G2: 5 (3.3) G1>G2, P = 0.002 Insomnia: G1: 20 (13.1) G2: 5 (3.3) G1>G2, P = 0.003 Fatigue: G1: 16 (10.5) G2: 3 (2.0) G1>G2, P = 0.003 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: − Drop-out rates: ++ Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Sussman and Garely, 2002 Country and setting: US, 2 sites Enrollment period: NR Funding: NR Author industry relationship disclosures: NR | Design: Multicenter RCT Intervention: Tolterodine ER vs. Oxybutynin ER Groups: G1: Tolterodine ER 2 mg qd × 8 wks G2: Tolterodine ER 4 mg qd x 8 wks G3: Oxybutynin ER 5 mg qd x 8 wks G4: Oxybutynin ER 10 mg qd x 8 wks N at enrollment: G1: 333 G2: 336 G3: 313 G4: 307 N at follow-up: G1: 313 (86) G2: 316 (88) G3: 286 (81) G4: 285 (79) Age, yrs ± SD: G1: 63.8 ± 15.7 G2: 63.4 ± 16.6 G3: 59.8 ± 16.5 G4: 63.2 ± 15.9 Women, N (%): G1: 243 (73) G2: 254 (76) G3: 245 (78) G4: 222 (72) Race/ethnicity, n (%): White: G1: 278 (84) G2: 296 (88) G3: 256 (82) G4: 247 (81) Black: G1: 28 (8) G2: 23 (7) G3: 41 (13) G4: 42 (14) Hispanic: G1: 19 (6) G2: 15 (5) G3: 15 (5) G4: 16 (5) Other, n (%): G1: 8 (2) G2: 2 (<1) G3: 1 (<1) G4: 2 (<1) Parity: NR | Inclusion criteria: • 18+ years old • OAB (urinary frequency + urgency) w/or w/o UI Exclusion criteria: • Pure SI • Urinary retention • Gastric retention • Uncontrolled narrow-angle glaucoma • Significant hepatic or renal dysfunction • Symptomatic or recurrent UTI • Electrostimulation • Bladder training • Pelvic floor exercise w/in 1 wk of first study visit or expected to start during study • Indwelling catheter • Intermittent self-cath • Contraindication to antimuscarinic trt • Estrogen therapy started less than 2 mos prior to first visit • Any trt for UI w/in 1 wk of first visit • Use of anticholinergic drug or potent inhibitors of cytochrome P450 3A4 • Pregnant • Lactating • Childbearing potential w/o adequate contraception | Presence of UI, n (%): G1: 195 (59) G2: 214 (64) G3: 199 (64) G4: 195 (64) Duration of sx, n (%): < 6 months: G1: 38 (11) G2: 48 (14) G3: 62 (20) G4: 43 (14) 6 months to 5 years: G1: 226 (68) G2: 224 (67) G3: 183 (59) G4: 205 (67) > 5 years: G1: 68 (20) G2: 64 (19) G3: 67 (21) G4: 59 (19) Severity of bladder condition, % No problems: G1: 1.3 G2: 0.3 G3: 1.0 G4: 0.7 Some very minor problems: G1: 6 G2: 5 G3: 5 G4: 5 Some minor problems: G1: 18 G2: 16 G3: 21 G4: 15 Moderate problems G1: 45 G2: 50 G3: 41 G4: 47 Severe problems: G1: 26 G2: 21 G3: 23 G4: 25 Many severe problems: G1: 4 G2: 7 G3: 8 G4: 8 | Improvement in bladder condition, 8 wks, overall, %: G1: 60 G2: 70 G3: 59 G4: 60 G2/G3: P < 0.01 G2/G4: P < 0.01 Improvement in bladder condition, 8 wks, moderate or severe bladder condition, %: G2: 77 G4: 65 G2/G4: P < 0.01 Improvement in bladder condition, 8 wks, treatment naïve, %: G1: 60 G2: 69 G3: 60 G4: 61 P = 0.11 for improvement rates P > 0.05 for overall difference btw trt arms Improvement in bladder condition, 8 wks, treatment experienced, %: G1: 57 G2: 75 G3: 59 G4: 54 P = 0.11 for improvement rates P > 0.05 for overall difference btw trt arms Withdrawal due to AE, (%): G2: 6 G4: 13 P = 0.001 Mean change in severity of dry mouth (visual analogue scale): G1: 2.3 G2: 6.0 G3: 6.3 G4: 11.3 G1 vs G2: P = NS G3 vs G4: P = 0.05 G2 vs G4: P = 0.03 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: + Masking: − Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: − Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Swift et al., 2003 Country and setting: Europe (167 centers), North America (74 centers), Australia and New Zealand (4 centers), University Enrollment period: February 1999 to October 1999 Funding: Pharmacia Corp Author industry relationship disclosures: NR | Design: RCT double blind placebo-controlled double dummy, random permuted blocks of 6 Intervention: Tolterodine ER vs. Tolterodine IR Groups: G1: Tolterodine ER 4 mg daily G2: Tolterodine IR 2 mg b.i.d. G3: placebo N at enrollment: G1: 417 G2: 408 G3: 410 N at follow-up: Total: 1092 Women, %: 100 Age, yrs ± SD: G1: 59 ± 14 G2: 59 ± 14 G3: 60 ± 14 Race/ethnicity, n (%): White: G1: 396 (95) G2: 389 (95) G3: 383 (93) Black: G1: 15 (4) G2: 12 (3) G3: 20 (5) Asian/Pacific: G1: 5 (1) G2: 4 (1) G3: 2 (1) Mixed: G1: 0 G2: 3 (1) G3: 5 (1) Unknown: G1: 1 (<1) G2: 0 G3: 0 BMI, kg/m^2^ ± SD: G1: 28.8 ± 13.8 G2: 29.0 ± 11.0 G3: 28.8 ± 6.7 | Inclusion criteria: • Women • Age ≥ 18 • ≥ 8 voids/day • > 5 UUI/week • Symptoms × ≥ 6 months (per voiding diary) Exclusion criteria: • SUI • Total daily urine volume > 3 liters • Hepatic/renal disease • UTI • IC • Hematuria • BOO • Current e-stim • Current bladder training • Indwelling catheter • CIC • Pregnant/nursing • Childbearing age without BC • Anticholinergic meds • Meds inhibit cytochromep450 | Incontinence episodes/week, mean ± SD: G1: 22.1 ± 22.5 G2: 22.9 ± 21.9 G3: 23.9 ± 21.2 Pads/day, mean ± SD: G1: 1.6 ± 2.1 G2: 1.5 ± 2.0 G3: 1.7 ± 2.4 Voids/day, mean ± SD: G1: 10.8 ± 4.2 G2: 11.1 ± 3.7 G3: 11.2 ± 3.9 Voided volume (mL), mean ± SD: G1: 141.2 ± 43.1 G2: 137.2 ± 41.2 G3: 135.7 ± 43.2 Previous drug therapy: n (%): G1: 235 (56) G2: 222 (54) G3: 225 (55) | Incontinence episodes/week, mean ± SD: G1: 10.3 ± 17.2 G2: 12.8 ± 19.8 G3: 16.7 ± 19.7 G1/G3: P = 0.001 G2/G3: P = 0.001 Pads/day, mean ± SD: G1: 1.0 ± 1.8 G2: 1.0 ± 1.5 G3: 1.5 ± 2.2 G1/G3: P = 0.001 G2/G3: P = 0.001 Voids/day, mean ± SD: G1: 9.0 ± 3.2 G2: 9.3 ± 4.0 G3: 9.9 ± 3.8 G1/G3: P = 0.001 G2/G3: P = 0.005 Voided volume (mL), mean ± SD: G1: 179.1 ± 66.6 G2: 169.7 ± 65.6 G3: 149.0 ± 56.3 G1/G3: P = 0.001 G2/G3: P = 0.001 Clinical effect-tiveness*, dry mouth: G1: 0.53 G2: 0.39 G3: 0.30 Dry mouth, n (%): G1: 105 (25.3) G2: 127 (31.2) G3: 33 (8.0) G1/G3: P < 0.01 G2/G3: P < 0.01 Abdominal pain, n (%): G1: 18 (4.3) G2: 12 (2.9) G3: 7 (1.7) G1/G3: P = 0.03 Constipation, n (%): G1: 27 (6.5) G2: 27 (6.6) G3: 14 (3.4) Dyspepsia, n (%): G1: 11 (2.7) G2: 14 (3.4) G3: 6 (1.5) Nausea, n (%): G1: 7 (1.7) G2: 9 (2.2) G3: 9 (2.2) Diarrhea, n (%): G1: 10 (2.4) G2: 14 (3.4) G3: 9 (2.2) Flatulence, n (%): G1: 8 (1.9) G2: 11 (2.7) G3: 6 (1.5) Xerophthalmia, n (%): G1: 16 (3.9) G2: 8 (2.0) G3: 8 (2.0) Abnormal vision, n (%): G1: 5 (1.2) G2: 4 (1.0) G3: 2 (0.5) Headache, n (%): G1: 29 (7.0) G2: 14 (3.4) G3: 19 (4.6) UTI, n (%): G1: 15 (3.6) G2: 11 (2.7) G3: 19 (4.6) Insomnia, n (%): G1: 7 (1.7) G2: 2 (0.5) G3: 9 (2.2) Somnolence, n (%): G1: 12 (2.9) G2: 11 (2.7) G3: 8 (2.0) Dizziness, n (%): G1: 7 (1.7) G2: 7 (1.7) G3: 4 (1.0) Hypertension, n (%): G1: 6 (1.4) G2: 4 (1.0) G3: 4 (1.0) Sinusitis, n (%): G1: 8 (1.9) G2: 2 (0.5) G3: 3 (0.7) Arthritis, n (%): G1: 1 (0.2) G2: 5 (1.2) G3: 1 (0.2) Dry skin, n (%): G1: 2 (0.5) G2: 5 (1.2) G3: 1 (0.2) | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: + Masking: + Pt selection criteria: + Loss to followup: ++ Drop-out rates: ++ Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Szonyi et al., 1995 Country and setting: UK Enrollment period: NR Funding: Smith & Nephew Pharmaceuticals Ltd Author industry relationship disclosures: NR | Design: RCT Intervention: Oxybutynin plus bladder training vs placebo plus bladder training Groups: G1: Oxybutynin 2.5 mg b.i.d. with dose titration on days 29 and 43 plus bladder training G2: placebo + bladder training N at enrollment: G1: 30 G2: 30 N at follow-up: G1:16 G2: 23 Women, n (%): 56 (93) Age, mean ± SD: 82.2 ± 6.06 Race/ethnicity: NR Weight (kg), mean ± SD: 67.4 ± 14.92 | Inclusion criteria: • Age > 70 • Frequency, urgency and UUI • Mobile • Able to keep diary Exclusion criteria: • UTI • Hepatic or renal disease • Glaucoma • Uncontrolled diabetes • Taking imipramine or propantheline | | Voids/2 weeks, median change (95% CI): G1/G2: 577 (−27.0, 6.0) P = 0.0025 Nocturia episodes/2 weeks, median change (95% CI): G1/G2: −6 (−5, 7.0) Daytime incontinence episodes/2 weeks, median change (95% CI): G1 vs. G2: −9.5 (−11.0, 3.0) Nocturia episodes/2 weeks, median change (95% CI): G1/G2: −1.0 (−3.0, 2.0) Patient assessment of benefit, %: 29 days: G1: 86 G2: 55 P = 0.02 43 days: G1: 71 G2: 59 P = 0.41 57 days: G1: 79 G2: 55 P = 0.09 Patient response, 29 days, n: Cure: G1: 1 G2: 0 Significant improvement: G1: 15 G2: 8 Marginal improvement: G1: 7 G2: 8 No change: G1: 5 G2: 13 Patient response, 57 days, n: Cure: G1: 4 G2: 3 Significant improvement: G1: 14 G2: 8 Marginal improvement: G1: 3 G2: 4 No change: G1: 7 G2: 14 Dry mouth, %: G1: 93 G2: 86 Blurred vision, %: G1: 50 G2: 59 Heartburn, %: G1: 57 G2: 45 Constipation, %: G1: 50 G2: 45 Dry skin, %: G1: 50 G2: 59 Poor compliance (< 75% of tablets), %: G1: 20 G2: 20 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: + Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Tseng et al., 2009 Country and setting: Taiwan, University Enrollment period: January 2005 to November 2005 Funding: NR Author industry relationship disclosures: NR | Design: Prospective cohort randomized Intervention: Tolterodine 2 mg b.i.d. vs. tolterodine 2 mg b.i.d. + conjugated equine estrogen 0.625 mg twice per week Groups: G1: tolterodine 2 mg b.i.d. G2: tolterodine 2 mg b.i.d. + conjugated equine estrogen 0.625 mg twice per week N at enrollment: G1: 40 G2: 40 N at follow-up: G1: 40 G2: 40 Age, mean ± SD: G1: 64.5 ± 7.4 G2: 66.2 ± 6.8 Race/ethnicity: NR Women, N (%): G1: 40 (100) G2: 40 (100) BMI, kg/m^2^ ± SD: G1: 24.5 ± 3.9 G2: 25.3 ± 3.8 Previous antimuscarinic Rx, n (%): G1: 5 (12.5) G2: 6 (15) Prior hysterictomy, n (%): G1: 12 (30) G2: 14 (35) | Inclusion criteria: • Age ≥ 18 • OAB symptoms • Amenorrheic Exclusion criteria: • Advanced POP > Stage 2 • Severe constipation • Elevated PVR • Neurological deficit • Renal/hepatic disease • Narrow angle glaucoma • Urinary retention • Gastric retention • Hypersensitivity to drugs • BOO • Cardiac conduction disorders • Myasthenia gravis • History of CVA • History of VTE • Gallbladder disease • Known or suspected breast carcinoma • Undiagnosed genital bleeding • HRT within 3 months of study enrollment | UUI episodes/day, mean ± SD: G1: 1.8 ± 0.7 G2: 2.1 ± 1.1 Urgency episodes/day, mean ± SD: G1: 4.5 ± 0.8 G2: 4.3 ± 0.7 Nocturia episodes/day, mean ± SD: G1: 3.5 ± 0.8 G2: 3.3 ± 0.8 Voids/day, mean ± SD: G1: 14.1 ± 1.3 G2: 14.8 ± 1.5 UDI-6 score, mean ± SD: G1: 9.5 ± 3.9 G2: 8.6 ± 3.8 IIQ-7 score, mean ± SD: G1: 10.2 ± 4.5 G2: 9.4 ± 3.6 Voided volume (mL), mean ± SD: G1: 108.5 ± 14.0 G2: 115.8 ± 15.1 | UUI episodes/day, mean ± SD: G1: 1.5 ± 0.5 G2: 1.5 ± 0.5 P = NS Urgency episodes/day, mean ± SD: G1: 3.5 ± 0.5 G2: 3.3 ± 0.6 Nocturia episodes/day, mean ± SD: G1: 2.9 ± 0.6 G2: 2.6 ± 0.7 Voids/day, mean ± SD: G1: 6.4 ± 1.9 G2: 5.8 ± 0.9 P = 0.001 UDI-6 score, mean ± SD: G1: 7.2 ± 2.9 G2: 6.9 ± 2.7 P < 0.001 IIQ-7 score, mean ± SD: G1: 6.5 ± 2.7 G2: 6.1 ± 2.5 P < 0.001 Voided volume (mL), mean ± SD: G1: 134.5 ± 15.8 G2: 141.9 ± 16.1 P = 0.007 Adverse events: None | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: + Method and blinding: − Pt selection criteria: + Loss to followup: ++ Drop-out rates: ++ Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Van Kerrebroeck et al., 2001 Freeman et al., 2003* Country and setting: North America (74 centers), Australasia (4 centers), Europe (89 centers) Enrollment period: NR Funding: Pharmacia Corporation Author industry relationship disclosures: NR | Design: RCT Intervention: Tolterodine ER vs Tolterodine IR vs placebo Groups: G1: tolterodine ER 4 mg qd G2: tolterodine IR 2 mg b.i.d. G3: placebo N at enrollment: G1: 507 G2: 514 G3: 508 N at follow-up: Total: 1442 G1: 398 G3: 374 Women, n (%): G1: 417 (82) G2: 408 (79) G3: 410 (81) Age, mean (range): G1: 60 (20, 89) G2: 60 (22, 92) G3: 61 (22, 93) Race/ethnicity, %:* White: G1: 95.7 G3: 94.7 Black: G1: 3.0 G3: 3.5 Asian/Pacific Islander: G1: 1.0 G3: 0.8 Other: G1: 0.3 G3: 1.1 | Inclusion criteria: • Age ≥ 18 • Urinary frequency (≥ 8 voids/day) Exclusion criteria: • SUI • Total daily urine volume > 3 L • Contra-indications to antimuscarinic treatment • Hepatic or renal disease • UITs • Interstitial cystitis • Hematuria • BOO • Current electrostimulation or bladder training therapy • Indwelling catheter or intermittent self-catheterization • Pregnant or nursing • Women not using reliable contraception • Being treated for OAB with other anticholinergic drugs or drugs that inhibit cytochrome P450 3A4 isoenzymes • Estrogen therapy < 2 months • Treatment w/investigational drug < 2 months | Incontinence episodes/week, mean (range): G1: 22.1 (0, 168.0) G2: 23.2 (0, 168.0) G3: 23.3 (0, 168.0) ≥ 5 incontinence episodes/week, n (%): G1: 492 (97) G2: 498 (97) G3: 494 (97) Pads/day, mean (range): G1: 1.4 (0–18) G2: 1.4 (0–25) G3: 1.5 (0–22) Voids/day, mean (range): G1: 10.9 (2.3, 51.3) G2: 11.1 (2.0, 48.6) G3: 11.3 (2.0, 37.4) ≥ 8 voids/day, n (%): G1: 458 (90) G2: 469 (91) G3: 467 (92) Previous drug therapy, n (%): G1: 270 (53) G2: 276 (54) G3: 263 (52) Poor efficacy, %: G1: 43 G2: 38.4 G3: 40.7 Able to finish tasks before visiting a toilet, %:* G1: 5 G3: 6 Voided volume (mL), mean (range): G1: 141 (36, 338) G2: 137 (38, 283) G3: 136 (31, 374) | Urgency, subject-tive assessment, 12 wks, n (%):* Improvement: G1: 173 (44) G3: 118 (32) G1/G3: P < 0.001 No change: G1: 201 (51) G3: 212 (57) Deterioration: G1: 22 (6) G3: 44 (12) G1/G3: P < 0.002 Urgency, improvement, 12 wks, women only, %:* G1: 46.6 G3: 26.6 G1/G3: P = 0.001 OR 1.81 (95% CI: 1.31, 2.49) Not able to hold urine, 12 wks, %:* G1: 58 G3: 32 G1/G3: P < 0.001 Incontinence episodes/week, mean change ± SD (%) G1: −11.8 ± 17.8 G2: −10.6 ± 16.9 G3: −6.9 ± 15.4 G1/G3: P = 0.00001 G2/G3: P = 0.0005 G1/G2: P < 0.05 Incontinence episodes/week, median % change: G1: −71 G2: −60 G3: −30 G1/G2: P < 0.05 Pads/day, mean ± SD: G1: −0.5 ± 1.4 G2: −0.5 ± 18 G3: −0.2 ± 1.4 G1/G3: P = 0.0145 G2/G3: P = 0.0035 Voids/day, mean ± SD: G1: −3.5 ± 4.9 G2: −3.3 ± 4.4 G3: −2.2 ± 4.0 G1/G3: P = 0.00001 G2/G3: P = 0.0002 Voluntary voids/day, mean ± SD: G1: −1.8 ± 3.4 G2: −1.7 ± 3.3 G3: −1.2 ± 2.9 G1 vs G3 G1/G3: P = 0.00047 G2/G3: P = 0.0079 Bladder symptoms, improvement, 12 wks, women only, %:* G1: 62.8 G3: 48.4 G1/G3: P = 0.001 OR 1.78 (95% CI: 0.34, 2.37) Treatment benefit, 12 wks, n (%):* Much benefit: G1: 172 (43.2) G3: 88 (23.5) G1/G3: P < 0.001 Little benefit G1: 138 (34.7) G3: 118 (31.6) No benefit G1: 88 (22.1) G3: 168 (44.9) Able to finish tasks before visiting a toilet, 12 wks, %:* G1: 33 G3: 18 G1/G3: P < 0.001Voided volume (mL), mean change ± SD: G1: +34 ± 51 G2: +29 ± 47 G3: +14 ± 41 G1/G3: P = 0.00001 G2/G3: P = 0.0001 Discontinued due to AEs, n (%): G1: 27 (5) G2: 28 (5) G3: 33 (6) Reported serious adverse events, n: G1: 7 G2: 12 G3: 18 Parasympathetic Dry mouth, n (%): G1: 118 (23) G2: 156 (30) G3: 39 (8) Xerophthalmia, n (%): G1: 17 (3) G2: 12 (2) G3: 10 (2) Abnormal vision, n (%): G1: 6 (1) G2: 4 (1) G3: 2 (0.5) Dry skin, n (%): G1: 2 (0.5) G2: 6 (1) G3: 1 (0.5) Gastrointestinal Constipation, n (%): G1: 30 (6) G2: 35 (7) G3: 22 (4) Dyspepsia, n (%): G1: 15 (3) G2: 16 (3) G3: 7 (1) Abdominal pain, n (%): G1: 19 (4) G2: 13 (3) G3: 8 (2) Diarrhea, n (%): G1: 10 (2) G2: 16 (3) G3: 11 (2) Flatulence, n (%): G1: 10 (2) G2: 14 (3) G3: 9 (2) Nausea, n (%): G1: 7 (1) G2: 10 (2) G3: 10 (2) Headache, n (%): G1: 32 (6) G2: 19 (4) G3: 23 (5) Somnolence, n (%): G1: 14 (3) G2: 13 (3) G3: 9 (2) Dizziness, n (%): G1: 11 (2) G2: 9 (2) G3: 5 (1) Fatigue, n (%): G1: 11 (2) G2: 6 (1) G3: 4 (1) Insomnia, n (%): G1: 7 (1) G2: 2 (0.5) G3: 9 (2) Urinary tract infection, n (%): G1: 16 (3) G2: 13 (3) G3: 20 (4) Dysuria, n (%): G1: 5 (1) G2: 8 (2) G3: 1 (0.5) Peripheral edema, n (%): G1: 7 (1) G2: 7 (1) G3: 4 (1) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: − Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Versi et al., 2000 Country and setting: US, 20 Academic health centers Enrollment period: NR Funding: ALZA Corp Author industry relationship disclosures: NR | Design: RCT Intervention: Oxybutynin CR vs Oxybutynin IR Doses were increased/decreased in 5 mg/d increments until optimal dose identified. Once identified the dose was maintained for 1 wk and urinary diary completed Groups: G1: Oxybutynin CR 5-20 mg/d G2: Oxybutynin IR 5-20 mg/d N at enrollment: G1: 111 G2: 115 N at follow-up: G1: 107 G2: 106 Age, yrs ± SD: G1: 58.8 G2: 59.6 Race/ethnicity, %: White: G1: 86.5 G2: 90.4 Black: G1: 5.4 G2: 3.5 Hispanic G1: 5.4 G2: 5.2 Asian: G1: 0.9 G2: 0 Native American G1: 0 G2: 0.9 Other G1: 2 G2: 0 Weight, mean kg: G1: 78.0 G2: 79.0 Height, mean cm: G1: 163.7 G2: 165.1 Women, %: G1: 88.3 G2: 90.4 Parity mean ± SD: NR | Inclusion criteria: • Known to be responsive to anticholinergic trt • 7–45 UI episodes per wk • Adult • Community-dwelling • 4+ days of incontinence/wk Exclusion criteria: • Clinically significant medical problems • PVR>100mL • Contraindication to oxybutynin | UUI episodes/week, mean: G1: 18.6 G2: 19.8 Incontinence episodes/week, mean: G1: 20.2 G2: 22.4 | UUI episodes/week, mean (%): G1: 2.9 (83) G2: 4.4 (76) P value for change from baseline: G1: P < 0.001 G2: P < 0.001 P = 0.36 for % reduction Incontinence episodes/week, mean (%): G1: 3.5 (81) G2: 5.4 (75) P value for change from baseline: G1: P < 0.001 G2: P < 0.001 P = 0.85 for % reduction Rates for Dry Mouth (%): G1: 47.7 G2: 59.1 P = 0.09 Pts reporting any dry mouth, cumulative %: Dose of 5mg/day: G1: 18.9 G2: 35.7 Dose of 10mg/day: G1: 39.5 G2: 61.2 Dose of 15 mg/day: G1: 56.8 G2: 74.1 Dose of 20 mg/day: G1: 80.1 G2: 82.7 G1/G2: P = 0.003 for all comparisons | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: - Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: - Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: - Measurement methods: + Measurement reliability: + Intervention description: +
Author: Wang et al., 2002 Country and setting: US, Health care database Enrollment period: January 1991 to June 1995 Funding: Pharmacia Author industry relationship disclosures: NR | Design: Healthcare database utilization claims analysis (retrospective cohort) Intervention: Urinary antispasmotics including flavoxate, oxybutynin, hyoscyamine and hyocyamine sulfate Groups: G1: Prescribed any urinary antispasmotic in interval G2: No prescriptions for urinary antispasmotic agents N in database: G1: 3,898 G2: 10,740 N at follow-up: NA Women, %: G1: 75.4 G2: 67.0 Age, mean: G1: 78.0 G2: 80.3 Race/ethnicity, %: White: G1: 82.9 G2: 82.5 Black: G1: 12.5 G2: 13.0 Other: G1: 4.6 G2: 4.5 | Inclusion criteria: • New Jersey residents in Medicaid/Medicare or Pharmacy Assistance for the Aged and Disabled with comprehensive prescription programs • Covered by programs from January 1990 to June 1995 • Age ≥ 65 • Diagnosis of urinary incontinence • Care utilization or prescription for any indication in the six months before and after the index date of the diagnosis of incontinence • Exclusion criteria: • No record of care utilization or prescriptions filled in the study interval | Charlson comorbidity index, mean score: G1: 1.8 G2: 2.6 P < 0.001 Hospital days in prior 180 days, mean: G1: 6.8 G2: 12.5 P < 0.001 Physician visits in prior 180 days, mean: G1: 7.3 G2: 5.4 P < 0.001 Nursing home days in prior 180 days, mean: G1: 17.0 G2: 36.8 P < 0.001 SES: Medicaid, %: G1: 51.5 G2: 65.7 P < 0.001 SES: PAAD, %: G1: 48.5 G2: 34.3 P < 0.001 Dx of CVD, %: G1: 18.2 G2: 25.2 P < 0.001 Dx of CHF, %: G1: 16.9 G2: 25.1 P < 0.001 Dx of conduction disturbance, %: G1: 3.0 G2: 3.9 P = 0.008 Dx of supra-ventricular dysrhythmia, %: G1: 7.8 G2: 12.2 P < 0.001 Dx of HTN, %: G1: 44.8 G2: 43.8 P = 0.255 Dx of Ischemic heart disease, %: G1: 31.0 G2: 36.7 P < 0.001 Dx of other CVD, %: G1: 28.0 G2: 35.0 P < 0.001 Dx of electrolyte abnormalities, %: G1: 6.4 G2: 11.8 P < 0.001 | Adjusted relative risk of ventricular arrhythmia, G1/G2 (95% CI): Urinary antispasmodic use: 1.23 (0.87, 1.75) Nonsedating antihistamine use: 0.95 (0.23, 3.84) Cytochrome P450 3A4 inhibitor use: 1.12 (0.60, 2.08) Concurrent nonsedating antihistamine/cytochrome inhibitor use: 5.47 (1.34, 22.26) Adjusted relative risk of sudden death, G1/G2 (95% CI): Urinary antispasmodic use: 0.70 (0.28, 1.74) Nonsedating antihistamine use: 1.43 (0.20, 10.35) Cytochrome P450 3A4 inhibitor use: 1.80 (0.86, 3.76) Concurrent nonsedating antihistamine/cytochrome inhibitor use: 21.50 (5.23, 88.37) Incidence rate of ventricular arrhythmia with medication use, (95% CI): Urinary antispasmodics: 1.08 (0.85, 1.37) Nonsedating antihistamines 1.00 (0.50, 1.99) Cytochrome P450 3A4 inhibitors: 1.02 (0.77, 1.34) Concurrent nonsedating antihistamine/cytochrome inhibitor use: 3.45 (1.11, 10.69) Incidence rate of sudden death with medication use, (95% CI): Urinary antispasmodics: 0.69 (0.29, 1.66) Nonsedating antihistamines: 1.14 (0.16, 8.06) Cytochrome P450 3A4 inhibitors: 1.51 (0.76, 3.02) Concurrent nonsedating antihistamine/cytochrome inhibitor use: 24.35 (6.09, 97.35) | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: NA Drop-out rates: NA Power calculation: − Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: NR Baseline characteristics: − Length of followup: NA Measurement methods: + Measurement reliability: + Intervention description: +
Author: Wang et al., 2006 Country and setting: Taiwan; Academic medical center Enrollment period: July 2004 to November 2005 Funding: National Science Council, Taiwan Author industry relationship disclosures: NR | Design: RCT Intervention: Electric Stimulation (ES) vs Oxybutynin vs Placebo for 12 weeks Groups: G1: ES: intravaginal electrode; biphasic symmetric pulsed current w/a 10-Hz frequency, 400-millisecond pulse width, 10/5 duty cycle, and varying intensity, 20 min/session, twice weekly G2: Oxybutynin, 2.5 mg 3 times daily G3: Placebo pill 3 times daily N at enrollment: G1: 25 G2: 26 G3: 23 N at follow-up: G1: 24 G2: 23 G3: 21 Age: NR Race/ethnicity: NR | Inclusion criteria: • Female • OAB for ≥ 6 mos • Age 16–80 • Urgency ≥ 4 times per day Exclusion criteria: • Use of anticholinergics or TCAs • Previous treatment with pelvic-floor muscle training, bladder training • Pelvic prolapse repair • Pregnancy • Neurologic disorders • DM • Demand cardiac pacemaker • IUD use • Genital prolapse greater than ICS Stage II • PVR>100 mL • Overt SI • Anti-incontinence surgery • UTI | UUI episodes/day, median (range): G1: 1 (0–2) G2: 0 (0–2) G3: 1 (0–2) Urgency episodes/day, median (range): G1: 11.4 (4.0–16.0) G2: 12.1 (5–18) G3: 9.8 (4.2–15.5) Voids/day, median (range): G1: 12.8 (8.8–16.0) G2: 11.5 (4.3–19.5) G3: 11.5 (6.5–22.8) Nocturia episodes/day, median (range): G1: 1.75 (0–6.5) G2: 0 (0–2.5) G3: 0.65 (0–3.1) Pads/day, median (range): G1: 1 (0–4.1) G2: 0 (0–3) G3: 1 (0–4) Warning time (sec), median (range): G1: 41.5 (8–105) G2: 44 (2–215) G3: 65 (26–265 Max voided volume (mL), median (range): G1: 340 (120–450) G2: 310 (130–800) G3: 350 (120–600) Total voided volume/day (mL), median (range): G1: 2160 (1010–2950) G2: 2106 (1560–3153) G3: 2305 (1305–3300) | UUI episodes/day, median (range): G1: 0.5 (0–2) G2: 0 (0–2) G3: 1 (0–2) G1/BL: P = 0.814 G2/BL: P = 0.083 G3/BL: P = 0.854 G1–G3: P = 0.413 Urgency episodes/day median (range): G1: 1.0 (0.0–12.3) G2: 6 (0.5–13) G3: 7.4 (3.9–13.4) G1/BL: P < 0.001 G2/BL: P < 0.001 G3/BL: P = 0.003 G1–G3: P < 0.001 Voids/day, median (range): G1: 7.8 (1.8–13.0) G2: 7.4 (2–14) G3: 10 (3.9–13.4) G1/BL: P < 0.001 G2/BL: P < 0.001 G3/BL: P = 0.070 G1–G3: P = 0.002 Nocturia episodes/day, median (range): G1: 0 (0–3.0) G2: 0 (0–2.5) G3: 1 (0–3.6) G1/BL: P = 0.001 G2/BL: P = 0.394 G3/BL: P = 0.176 G1–G3: P = 0.002 Pads/day, median (range): G1: 0 (0–2) G2: 0 (0–2.5) G3: 1 (0–3) G1/BL: P = 0.010 G2/BL: P = 0.662 G3/BL: P = 0.501 G1–G3: P = 0.012 Warning time (sec), median (range): G1: 72 (32–633) G2: 54.5 (138–850) G3: 66.5 (26–219) G1/BL: P = 0.002 G2/BL: P = 0.001 G3/BL: P = 0.532 G1–G3: P < 0.001 Max voided volume (mL), median (range): G1: 355 (150–550) G2: 336.5 (138–850) G3: 340 (160–600) G1/BL: P = 0.018 G2/BL: P = 0.004 G3/BL: P = 0.979 G1–G3: P = 0.035 Total voided volume/day (mL), median (range): G1: 2270 (1210–3106) G2: 2100 (1619–3200) G3: 2305 (1351–3221) G1/BL: P = 0.024 G2/BL: P = 0.728 G3/BL: P = 0.627 G1–G3: P = 0.050 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: − Pt selection criteria: + Loss to followup: ++ Drop-out rates: + Power calculation: + Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Yamaguchi et al., 2007 Country and setting: Japan, 155 academic health centers Enrollment period: June 2003 to January 2004 Funding: Astellas Pharma Inc. Author industry relationship disclosures: 2 of 12 Astellas (2) | Design: RCT, double-blind, double-dummy, placebo controlled Intervention: solifenacin vs propiverine vs placebo Groups: G1: solifenacin 5 mg qd × 12 wks G2: solifenacin 10 mg qd × 12 wks G3: propiverine 20 mg qd × 12 wks G4: placebo qd × 12 wks N at enrollment: G1: 398 G2: 381 G3: 400 G4: 405 N at follow-up: G1: 364 G2: 349 G3: 364 G4: 371 Women, n (%): G1: 318 (83.0) G2: 318 (85.7) G3: 321 (83.6) G4: 333 (84.3) Age, mean ± SD, (range): G1: 60.4 ± 13.3 (20.0–89.0) G2: 59.9 ± 13.0 (20.0–86.0) G3: 59.6 ± 13.6 (23.0–94.0) G4: 60.8 ± 12.5 (28.0–90.0) Age ≥ 65, N (%): G1: 161 (42.0) G2: 157 (42.3) G3: 166 (43.2) G4: 163 (41.3) Race/ethnicity: NR Weight (kg), mean ± SD (range): G1: 56.3 ± 9.7 (30.5–123.0) G2: 57.1 ± 10.5 (35.0–117.4) G3: 56.6 ± 10.0 (33.0–103.0) G4: 56.2 ± 9.4 (36.0–90.0) | Inclusion criteria: • Age ≥ 20 • OAB sx for ≥ 6 mos • ≥ 8 voids/day • ≥ 3 episodes of urgency or ≥ 3 episodes of urgency incontinence over 72 hours Exclusion criteria: • PVR >100 mL • Significant BOO • Urinary retention • SI • Bladder stones • UTI • Interstitial cystitis • Previous or current malignant dz of the pelvic organs • Previous pelvic radiation • Current trt w/anticholinergic meds • Known or suspected hypersensitivity to anticholinergic meds or lactose | UUI episodes/day, mean ± SD: G1: 1.95 ± 2.14 G2: 1.89 ± 1.91 G3: 1.82 ± 1.94 G4: 1.67 ± 1.95 Urgency episodes, n: G1: 383 G2: 371 G3: 384 G4: 395 Urgency episodes/day, mean ± SD: G1: 4.40 ± 3.38 G2: 4.47 ± 3.30 G3: 4.07 ± 3.19 G4: 4.04 ± 3.11 Incontinent, n: G1: 274 G2: 270 G3: 295 G4: 283 Incontinence type, n (%): Urge: G1: 235 (61.4) G2: 213 (57.4) G3: 218 (56.8) G4: 244 (61.8) Mixed: G1: 130 (33.9) G2: 143 (38.5) G3: 144 (37.5) G4: 135 (34.2) None: G1: 18 (4.7) G2: 15 (4.0) G3: 22 (5.7) G4: 16 (4.1) Incontinence episodes/day, mean ± SD: G1: 2.35 ± 2.45 G2: 2.19 ± 2.04 G3: 2.15 ± 2.31 G4: 1.99 ± 2.11 Voids/day, mean ± SD G1: 11.44 ± 2.94 G2: 11.15 ± 2.76 G3: 11.37 ± 2.71 G4: 11.25 ± 2.73 ≥ 8 voids/day, n: G1: 383 G2: 371 G3: 384 G4: 395 Nocturia episodes/day, mean ± SD: G1: 1.91 ± 1.22 G2: 1.78 ± 1.04 G3: 1.95 ± 1.29 G4: 1.84 ± 1.10 Duration of symptoms (years), n (%): ≥ 0.5 to < 1: G1: 46 (12.0) G2: 36 (9.7) G3: 38 (9.9) G4: 39 (9.9) ≥ 1 to < 3: G1: 89 (23.2) G2: 97 (26.1) G3: 85 (22.1) G4: 81 (20.5) ≥ 3 to < 5: G1: 34 (8.9) G2: 45 (12.1) G3: 38 (9.9) G4: 40 (10.1) ≥ 5 to < 10: G1: 24 (6.3) G2: 23 (6.2) G3: 22 (5.7) G4: 37 (9.4) ≥ 10 G1: 23 (6.0) G2: 14 (3.8) G3: 20 (5.2) G4: 24 (6.1) Unknown: G1: 167 (43.6) G2: 36 (9.7) G3: 38 (9.9) G4: 39 (9.9) Volume voided, mean mL ± SD: G1: 153.4 ± 52.91 G2: 154.4 ± 50.21 G3: 151.2 ± 49.38 G4: 152.8 ± 44.28 | UUI episodes/day, mean change ± SD: G1: −1.45 ± 1.89 G2: −1.52 ± 1.77 G3: −1.19 ± 2.20 G4: −0.69 ± 2.00 G1/G4: P < 0.001 G2/G4: P < 0.001 G3/G4: P < 0.025 Urgency free, n (%): G1: 126 (32.9) G2: 138 (37.2) G3: 128 (33.3) G4: 82 (20.8) Urgency episodes/day, mean change ± SD: G1: −2.41 ± 2.88 G2: −2.78 ± 2.82 G3: −2.30 ± 3.08 G4: −1.28 ± 2.90 G1/G4: P < 0.001 G2/G4: P < 0.001 G3/G4: P < 0.001 G2/G3: P = 0.012 Continent, n (%): G1: 154 (56.2) G2: 161 (59.6) G3: 165 (55.9) G4: 105 (37.1) Incontinence episodes/day, mean change ± SD: G1: −1.59 ± 2.12 G2: −1.60 ± 1.81 G3: −1.25 ± 2.79 G4: −0.72 ± 1.95 G1/G4: P < 0.001 G2/G4: P < 0.001 G3/G4: P < 0.025 Voids/day, mean change ± SD: G1: −1.93 ± 1.97 G2: −2.19 ± 2.09 G3: −1.87 ± 2.70 G4: −0.94 ± 2.29 G1/G4: P < 0.001 G2/G4: P < 0.001 G3/G4: P < 0.001 G1/G3: P = NS G2/G3: P = NS ≥ 8 voids/day, n (%): G1: 109 (28.5) G2: 137 (36.9) G3: 101 (26.3) G4: 83 (21.0) Nocturia episodes/day, mean change ± SD: G1: −0.41 ± 0.96 G2: −0.46 ± 0.90 G1: −0.43 ± 1.21 G4: −0.30 ± 0.91 G1/G4: P = NS G2/G4: P < 0.025 G3/G4: P = NS KHQ, general health:^*^ G1/G4: P < 0.05 G3/G4: P < 0.05 KHQ, incontinence impact:^*^ G1/G4: P < 0.05 G2/G4: P < 0.05 G3/G4: P < 0.05 KHQ, role limitations:^*^ G1/G4: P < 0.05 G2/G4: P < 0.05 G3/G4: P < 0.05 KHQ, physical limitations:^*^ G1/G4: P < 0.05 G2/G4: P < 0.05 G3/G4: P < 0.05 KHQ, social limitations:^*^ G1/G4: P < 0.05 G2/G4: P < 0.05 G3/G4: P < 0.05 KHQ, personal relationships:^*^ G2/G4: P < 0.05 G3/G4: P < 0.05 KHQ, emotions:^*^ G1/G4: P < 0.05 G2/G4: P < 0.05 G3/G4: P < 0.05 KHQ, sleep/energy:^*^ G1/G4: P < 0.05 G2/G4: P < 0.05 G3/G4: P < 0.05 KHQ, severity:^*^ G1/G4: P < 0.05 G2/G4: P < 0.05 G3/G4: P < 0.05 G2/G3: P < 0.05 Voided volume (mL), mean change ± SD: G1: 35.78 ± 43.49 G2: 43.59 ± 44.52 G3: 36.62 ± 37.99 G4: 11.67 ± 33.74 G1/G4: P < 0.001 G2/G4: P < 0.001 G3/G4: P < 0.001 G2/G3: P = 0.009 Discontinued due to AEs, n (%): G1: 20 (5.1) G2: 26 (6.8) G3: 26 (6.5) G4: 11 (2.7) Dry mouth, n (%): G1: 67 (16.9) G2: 130 (34.1) G3: 103 (25.8) G4: 23 (5.7) G1/G3: P = 0.003 G2/G3: P = 0.012 Dry mouth, mild, n (%): G1: 64 (16.2) G2: 124 (32.5) G3: 100 (25.0) G4: 23 (5.7) Dry mouth, moderate, n (%): G1: 3 (0..8) G2: 6 (1.6) G3: 3 (0.8) G4: 1 (0.2) Constipation, n (%): G1: 42 (10.6) G2: 72 (18.9) G3: 45 (11.3) G4: 16 (4.0) G2/G3: P = 0.004 Blurred vision, n (%): G1: 7 (1.8) G2: 14 (3.7) G3: 15 (3.8) G4: 8 (2.0) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: + Pt selection criteria: + Loss to followup: ++ Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Zinner et al., 2002 [See evidence table for Van Kerrebroeck et al., 2001] Country and setting: North America (74 centers), Australasia (4 centers), Europe (89 centers) Enrollment period: NR Funding: Pharmacia Corporation Author industry relationship disclosures: NR | Design: RCT Intervention: Tolterodine ER vs placebo Groups: G1: tolterodine ER 4 mg qd < 65 years of age G2: placebo < 65 years of age G3: tolterodine ER 4 mg qd ≥ 65 years of age G4: placebo ≥ 65 years of age N at enrollment: G1: 293 G2: 285 G3: 214 G4: 223 N at follow-up: G1: 257 G2: 246 G3: 193 G4: 194 Women, n (%): G1: 255 (87)^**^ G2: 247 (87)^**^ G3: 162 (76) G4: 163 (73) Age, mean ± SD: G1: 51 ± 10.5 G2: 51 ± 10 G3: 74 ± 6 G2: 74 ± 6 Race/ethnicity: NR | Inclusion criteria: • Age ≥ 18 • Urinary frequency (≥ 8 voids/day) Exclusion criteria: • Demonstrable SUI • Total daily urine volume > 3 L • Contra-indications to antimuscarinic treatment • Hepatic or renal disease • UTI • Interstitial cystitis • Hematuria • BOO • Current electrostimulation or bladder training therapy • Indwelling catheter or intermittent self-catheterization • Pregnant or nursing • Women not using reliable contraception • Being treated for OAB with other anticholinergic drugs or drugs that inhibit cytochrome P450 3A4 isoenzymes • Estrogen therapy < 2 months • Treatment w/investigational drug < 2 months | Not able to hold urine upon experiencing urgency, %: G1: 24.9 G2: 29.1 G3: 33.6 G4: 34.5 Able to complete tasks before toilet visit in response to urgency,%: G1: 6.5 G2: 7.7 G3: 5.1 G4: 4.9 Incontinence episodes/week, mean ± SD: G1: 21.4 ± 22.1 G2: 23.2 ± 22.0 G3: 23.2 ± 22.7 G4: 23.4 ± 18.9 Voids/day, mean ± SD: G1: 11.0 ± 3.9 G2: 11.4 ± 4.2 G3: 10.8 ± 4.5 G4: 11.0 ± 3.2 Voided volume (mL), mean ± SD: G1: 140 ± 41 G2: 137 ± 45 G3: 141 ± 45 G4: 134 ± 39 Previous drug therapy, n (%): G1: 148 (50.5) G2: 146 (51.2) G3: 121 (56.5) G4: 117 (52.5) Percentage with poor efficacy, %: G1: 74 (50.0)^**^ G2: 60 (41.1)^**^ G3: 40 (33.1) G4: 46 (39.3) | Not able to hold urine upon experiencing urgency, %: G1: 11.3 G2: 21.1 G3: 15.9 G4: 25.6 G1/G2: P = 0.003 G3/G4: P = 0.007 No age-related difference Able to complete tasks before toilet visit in response to urgency,%: G1: 32.8 G2: 16.8 G3: 26.2 G4: 14.8 G1/G2: P = 0.001 G3/G4: P = 0.003 No age-related difference Incontinence episodes/week, mean ± SD G1: −12.0 ± 17.6 G2: −7.4 ± 15.6 G3: −11.5± 18.2 G4: −6.3 ± 15.0 G1/G2: P = 0.001 G3/G4: P < 0.001 No age-related difference Voids/day, mean ± SD G1: −2.0 ± 3.1 G2: −1.4 ± 3.1 G3: −1.4± 3.7 G4: −0.9 ± 2.6 G1/G2: P = 0.26 G3/G4: P = 0.92 Perception of bladder condition, improved, %: G1: 60.1 G2: 51.9 G3: 54.2 G4: 31.4 G1/G2: P < 0.05 G3/G4: P < 0.0001 Perception of bladder condition, no change, %: G1: 32.4 G2: 38.9 G3: 38.3 G4: 51.1 G4/G2: P < 0.0001 Perception of bladder condition, deterioration, %: G1: 7.2 G2: 9.1 G3: 7.5 G4: 17.5 Treatment beneficial, %: G1: 78.3 G2: 58.3 G3: 69.8 G4: 46.9 G1/G2: P = 0.001 G3/G4: P = 0.001 No age-related difference Voided volume (mL), mean ± SD: G1: 35 ± 53 G2: 13 ± 41 G3: 33± 47 G4: 16 ± 41 G1/G2: P < 0.001 G3/G4: P < 0.001 No age-related difference Adverse events, %: G1: 50.7 G2: 50.5 G3: 54.2 G4: 46.0 Dry mouth, severe, % G1–G2: 1.7 G3–G4: 1.9 Dry mouth, moderate, % G1–G2: 7.6 G3–G4: 6.5 Dry mouth, mild, % G1–G2: 13.4 G3–G4: 15.9 No dry mouth, % G1–G2: 77.3 G3–G4: 75.7 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: NR Power calculation: − Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Zinner et al., 2004 Country and setting: US, 51 sites Enrollment period: NR Funding: Indevus Corporation Author industry relationship disclosures: 4 of 5 Alza (1) Indevus (4) Kyowa (1) Lilly (2) Merck (1) Ortho-McNeil (1) Pfizer (2) Pharma (1) Pharmacia (1) Schwarz (1) Watson (2) Yamanouchi (1) | Design: RCT with 2 wk washout period Intervention: Trospium chloride vs placebo Groups: G1: Tropsium chloride 20 mg b.i.d. G2: placebo N at enrollment: G1: 262 G2: 261 N at follow-up: G1: 256 G2: 256 Women, n (%): G1: 203 (77.5) G2: 186 (71.3) Age, mean ± SD: G1: 63 ± 0.8 G2: 61.5 ± 0.8 Race/ethnicity, n (%): White: G1: 222 (84.7) G2: 225 (86.2) Black: G1: 26 (9.9) G2: 20 (7.7) Hispanic: G1: 10 (3.8) G2: 13 (5.0) Other: G1: 4 (1.6) G2: 3 (1.1) | Inclusion criteria: • Age ≥18 years • OAB symptoms ≥ 6 mos • Urinary urgency • ≥ 70 voids per week • ≥ 7 UUI episodes/week Exclusion criteria: • Stress predominant MUI • Insensate or overflow • Neurogenic bladder disorders • Significant renal disease • Hematuria hematuria and UTI at washout or ≥ twice in the prior year • BOO with PVR ≥ 100 mL • Concurrent use of any anticholinergic drug or other drug therapy for OAB within 21 days before randomization • Bladder surgery ≤ 6 mos • Bladder cancer • Interstitial cystitis • PSA ≥ 10 ng/mL • Diuretic use, estrogen therapy and nonmedical bladder therapy that was not part of a stable, long-term program. | UUI episodes/day, mean: G1: 3.9 G2: 4.3 Urgency episodes/day, mean: G1: 11.29 G2: 11.72 Urgency severity score, mean: G1: 1.8 G2: 1.8 Voids/day, mean: G1: 12.7 G2: 12.9 Daytime voids/day, mean: G1: 10.6 G2: 10.9 Nocturia episodes/day, mean: G1: 2.1 G2: 2.0 Voided volume (mL), mean: G1: 155.1 G2: 156.1 IIQ, mean score (SE): G1: 183.5 (5.6) G2: 195.4 (5.6) IIQ,, women only, mean score (SE): G1: 191.2 (6.3) G2: 201.9 (6.6) Incontinence Impact Questionnaire, travel subscale, score (SE): G1: 52.4 (1.7) G2: 55.6 (1.7) IIQ, social relationships, score (SE): G1: 37.8 (1.5) G2: 40.3 (1.5) IIQ, emotional health, mean score (SE): G1: 47.1 (1.6) G2: 49.6 (1.6) IIQ,, physical activity, mean score (SE): G1: 46.1 (1.6) G2: 50.2 (1.6) Prior OAB med, n (%): G1: 135 (51.5) G2: 142 (54.5) | UUI episodes/day, week 1, mean % change: G1: −40.1 G2: −27.5 G1/G2: P ≤ 0.001 UUI episodes/day, week 4, mean % change: G1: −58.5 G2: −40.9 G1/G2: P ≤ 0.0001 UUI episodes/day, week 12, mean % change: G1: −59.0 G2: −44.2 G1/G2: P ≤ 0.0001 Urgency episodes/day, week 1, mean change: G1: −1.13 G2: −1.08 Urgency episodes/day, week 4, mean change: G1: −2.10 G2: −1.00 G1/G2: P ≤ 0.0001 Urgency episodes/day, week 12, mean change: G1: −2.30 G2: −1.08 G1/G2: P ≤ 0.0001 Urgency severity score, week 1, mean change: G1: −0.11 G2: −0.01 G1/G2: P ≤ 0.01 Urgency severity score, week 4, mean change: G1: −0.18 G2: −0.06 G1/G2: P ≤ 0.01 Urgency severity score, week 12, mean change: G1: −0.22 G2: −0.04 G1/G2: P ≤ 0.001 Voids/day, week 1, mean change: G1: −1.18 G2: −0.81 G1/G2: P ≤ 0.05 Voids/day, week 4, mean change: G1: −2.20 G2: −1.07 G1/G2: P ≤ 0.0001 Voids/day, week 12, mean change: G1: −2.37 G2: −1.29 G1/G2: P ≤ 0.0001 Daytime voids/day, week 1, mean change: G1: −1.00 G2: −0.68 G1/G2: P ≤ 0.05 Daytime voids/day, week 4, mean change: G1: −1.77 G2: −0.89 G1/G2: P ≤ 0.0001 Daytime voids/day, week 12, mean change: G1: −1.90 G2: −0.98 G1/G2: P ≤ 0.0001 Nocturia episodes/day, week 1, mean change: G1: −0.18 G2: −0.15 Nocturia episodes/day, week 4, mean change: G1: −0.43 G2: −0.17 G1/G2: P ≤ 0.001 Nocturia episodes/day, week 12, mean change: G1: −0.47 G2: −0.29 G1/G2: P ≤ 0.05 Voided volume (mL), week 1, mean change: G1: 19.9 G2: 6.6 G1/G2: P ≤ 0.0001 Voided volume (mL), week 4, mean change: G1: 30.0 G2: 8.5 G1/G2: P ≤ 0.0001 Voided volume (mL), week 12, mean change: G1: 32.1 G2: 7.7 G1/G2: P ≤ 0.0001 IIQ, week 12, LS mean change (SE): G1: −54.0 (5.6) G2: −36.0 (5.6) G1/G2: P ≤ 0.05 IIQ, women only, week 12, LS mean change (SE): G1: −59.1 (6.6) G2: −35.7 (6.9) G1/G2: P ≤ 0.05 IIQ, travel subscale, week 12, LS mean change (SE): G1: −14.9 (1.7) G2: −9.9 (1.7) G1/G2: P < ≤ 0.05 IIQ, social relationsips, week 12, LS mean change (SE): G1: −10.8 (1.4) G2: −6.3 (1.4) G1/G2: P ≤ 0.05 IIQ, emotional health, 12 weeks, LS mean change (SE): G1: 14.1 (1.5) G2: −9.2 (1.5) G1/G2: P ≤ 0.05 IIQ, physical activity, 12 weeks, LS mean change (SE): G1: −13.5 (1.7) G2: −11.0 (1.7) Dry mouth, n (%): G1: 57 (21.8) G2: 17 (6.5) Constipation, n (%): G1: 25 (9.5) G2: 10 (3.8) Headache, n (%): G1: 17 (6.5) G2: 12 (4.6) Diarrhea, n (%): G1: 8 (3.1) G2: 14 (5.4) Abdominal pain, n (%): G1: 8 (3.1) G2: 3 (1.1) Discontinuation due to AE, %: G1: 8.8 G2: 5.7 | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: + Masking: − Pt selection criteria: + Loss to followup: ++ Drop-out rates: + Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Zinner et al., 2005 Country and setting: US, Specialty treatment center Enrollment period: NR Funding: Pfizer Novartis Pharma Thomson ACUMED Author industry relationship disclosures: NR | Design: Randomized double- blind placebo- controlled four way crossover Intervention: Darifenacin 15 mg qd vs darifenacin 30 mg qd vs. Oxybutynin vs. placebo Groups: * G1: Darifenacin 15mg daily G2: Darifenacin 30mg daily G3: Oxybutynin 5 mg t.i.d. G4: placebo N at enrollment: G1–G4: 76 N included, tolerability: G1–G4: 61 N included, efficacy: G1–G4: 58 Women, n (%): G1–G4: 71 (93.4) Age, mean (range): G1–G4: 59.9 (33–84) Race/ethnicity: NR Weight (kg), mean (range): G1–G4: 75.7 (42–157) | Inclusion criteria: • Age 18–85 • ≥ 4 UUI episodes/week • ≥ 8 voids/day (from 14 day run in placebo voiding diary) Exclusion criteria: • Neurogenic bladder • SUI • Contraindication to antimuscarinic treatment • UTI • Bladder symptoms • Bladder stones • BOO • Concomitant disease • Concurrent bladder training • Concurrent thyroid or HRT • Other bladder meds • Pregnant or breastfeeding | Urgency episodes/day, mean ± SD: G1–G 4: 9.3 ± 3.4 Urgency severity, mean ± SD: G1–G4: 2.0 ± 0.4 Incontinence episodes/week, mean ± SD: G1–G4: 20.4 ± 17.7 Voids/day, mean ± SD: G1–G4: 10.4 ± 3.0 | Urgency episodes/day, mean: G1: 7.95 G2: 7.59 G3: 8.12 G4: 8.71 G1–G3/G4: P < 0.05 Urgency severity, mean: G1: 1.93 G2: 1.84 G3: 1.89 G4: 2.03 G1–G3/G4: P < 0.05 Incontinence episodes/week, mean: G1: 10.93 G2: 8.82 G3: 9.45 G4: 14.64 G1–G3/G4: P < 0.05 Voids/day, mean ± SD: G1: 9.33 G2: 8.85 G3: 9.24 G4: 9.62 G2/G4: P < 0.05 Dry mouth, (%): G1: 13.1 G2: 34.4 G3: 36.1 G4: 4.9 G1/G3: P < 0.05 G2/G3: P < 0.05 G2/G4: P < 0.05 G3/G4: P < 0.05 Constipation, (%): G1: 9.8 G2: 21.3 G3: 8.2 G4: 3.3 G2/G3: P < 0.05 G2/G4: P < 0.05 Blurred vision, (%): G1: 0 G2: 0 G3: 3.3 G4: 0 Dizziness, (%): G1: 0 G2: 0 G3: 1.6 G4: 0 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: − Drop-out rates: NR Power calculation: + Statistical issues: + EXTERNAL VALIDITY: fair Age: −, NR Baseline OAB status: NR Baseline characteristics: − Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Zinner et al., 2006 Country and setting: NR, Multicenter Enrollment period: NR Funding: Novartis Author industry relationship disclosures: 5 of 6 Alza (1) Eli Lilly (2) Astellas (1) GSK (1) Indevus (1) Madaus (1) Novartis (5) Pfizer (2) Sanofi (1) Watson (2) Yamanouchi (1) | Design: RCT Intervention: Darifenacin 15 mg controlled release once daily vs. placebo Groups: G1: Darifenacin 15 mg controlled release once daily G2: Placebo N at enrollment: G1: 214 G2: 225 N at follow-up: G1: 185 G2: 188 Women, n (%): G1: 185 (86.4) G2: 198 (88.0) Age, mean (range): G1: 59.1 (20–93) G2: 59.1 (18–89) Race/ethnicity: NR | Inclusion criteria: • Adults • Age ≥18 • History of OAB for ≥ 6 mos • ≥ 1 urge incontinence episodes/day • ≥ 8 voids/day • ≥ 4 urgency episodes/day • Mean warning time of ≤ 15 min during 12 hrs Exclusion criteria: • SUI • Marked cystocele • Pelvic prolapse • Use of anticholinergics, antispasmodics, cholinergic agonists, potent cytochrome P450 3A4 inhibitors, or opioids 2 wks prior to screening visit • Contraindications to drugs that cause significant constipation, clinically significant bladder outlet obstruction • Intention to start bladder training program • In-dwelling catheter • Intermittent self-catheterization | UUI episodes/wk, median: G1: 18.73* G2: 21.00^ Urgency episodes/wk, median: G1: 82.60* G2: 85.40^ Warning time (min), mean: G1: 4.38* G2: 4.74* Warning time (min), median: G1: 2.57* G2: 3.04* Voids/day, median: G1: 11.00* G2: 11.20^ Duration of OAB (years), mean (range): G1: 7.8 (0, 45) G2: 8.3 (0, 58) Previous OAB therapy, n (%): G1: 112 (52.3) G2: 124 (55.1) Voided volume (mL), median: G1: 153.50* G2: 144.62^ | UUI episodes/wk, wk 2, median change: G1: −9.1 G2: −7.0 P < 0.01 UUI episodes/wk, wk 6, median change: G1: −11.2 G2: −8.4 P = 0.031 UUI episodes/wk, wk 12, median change: G1: −12.60 G2: −9.80 P = 0.035 Urgency episodes/wk, wk 12, median change: G1: −18.20 G2: −15.58 P = 0.18 Urgency-free time, (min), median: G1: 34.3 G2: 25.0 P = 0.003 Warning time, median % change: G1: 41.8 G2: 18.4 Voids/day, wk 12, median change: G1: −2.20 G2: −1.80 P = 0.176 Voided volume (mL), wk 12, mean change: G1: 22.62 G2: 11.31 P = 0.002 Total OAB-q score, wk 6, mean change: G1: 24.5 G2: 18.7 P = 0.035 Total OAB-q score, wk 12, mean change: G1: 26.4G2: 19.1 P < 0.001 Incontinence Impact, wk 12, mean change: G1: −24.7 G2: −17.8 P = 0.022 Severity measures, wk 12, mean change: G1: −24.3 G2: −15.6 P < 0.001 Adverse events, %: G1: 63.6 G2: 48.9 Discontinuation, n (%): G1: 17 (7.9) G2: 9 (4) Dry mouth and constipation, n (%): G1: 29.0 (17.8) G2: 5.8 (4.9) Discontinuation due to dry mouth, %: G1: 2.3 G2: 0 Discontinuation due to constipation, %: G1: 2.3 G2: 0 Headaches, %: G1: 6.1 G2: 2.2 Cardiac AEs, %: G1: 0.5 G2: 0.9 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Zinner et al. 2008 Country and setting: US, 89 sites Enrollment period: NR Funding: Astellas Pharma US, GlaxoSmithKline Author industry relationship disclosures: 5 of 5 Astellas (5) Esprit (2) Watson (3) Allergan (2) Medtronics (1) GlaxoSmithKline (3) Indevus (1) | Design: open label, non-comparative, flexible-dosing Intervention: solifenacin 5 or 10 mg qd for 12 wks after washout from tolterodine, with dose adjustments at wk 4 and wk 8 Groups: NA N at enrollment: 440 N at follow-up: 390 Age, yrs ± SD: 61.5 ± 13.69 Age < 65, n (%): 246 (55.9) Age ≥ 65–74, n (%): 108 (24.5) Age ≥ 75, n (%): 86 (19.5) Race/ethnicity, n (%): Caucasian 391 (88.9) Black or African 37 (8.4) Asian 1 (0.2) Other 11 (2.5) Women, N (%): 388 (88.2) Women < 65 yrs, n (%): 227 (58.5) Women Age ≥ 65–74, n (%): 92 (23.7) Women Age ≥ 75, (%): 69 (17.8) Height, mean cm ± SD: 164.1 ± 8.39 Weight, mean kg ± SD: 81.1 ± 20.56 BMI, mean kg/m^2^ ± SD: 30.1 ± 7.12 | Inclusion criteria: • Age ≥ 18 • Symptoms of OAB ≥ 3 mos • Ambulatory and able to use toilet without difficulty • Treated with tolterodine ER 4 mg/day at least 4 wks preceding study but failed to achieve satisfactory improvement in urgency episodes • ≥3 urgency episodes/24 hrs documented in 3-day voiding diary while receiving tolterodine ER 4 mg/d • Prior drug or other treatment for OAB with ≥ 4 wks washout before screening Exclusion criteria: • Prior treatment with darifenacin • SUI • Stress dominant MUI • UTI • Interstitial cystitis • Bladder stones • Outflow obstruction due to benign prostatic hyperplasia • Uncontrolled narrow-angle glaucoma • Urinary or gastric retention • Severe renal or hepatic impairment • Chronic severe constipation • Gastrointestinal obstructive disease • Bladder cancer • Pregnant or breast-feeding • Not using a reliable birth control method • Known hypersensitivity to solifenacin or to anticholinergic medicines • Participating in any clinical trial of any investigational drug within 30 days | Urgency episodes/day, mean: 6.03 Voids/day, mean: 10.59 Incontinence episodes/day, mean: 3.04 Nocturia episodes/day, mean: 1.83 Nocturnal voids/day, mean: 2.32 Pads or diapers/week, mean: 10.7 | Urgency episodes/day, mean change (95% CI): −3.41 (−3.79, −3.04)* Voids/day, mean change (95% CI): −1.57 (−1.86, −1.28)* Incontinence episodes/day, mean change (95% CI): −1.86 (−2.19, −1.53)* Nocturia episodes/day, mean change (95% CI): −0.72 (−0.84, −0.59)* Nocturnal voids/day, mean change (95% CI): −0.79 (−0.95, −0.62)* Pads or diapers/week, mean change: 7.9 P = 0.0009 Improvement in HRQL, mean (95% CI): 21.1 (19.0, 23.1)* Change in symptom bother score, mean (95% CI):^ −27.4 (−29.7, −25.1)* Change in coping, score, mean (95% CI)^: 23.1 (20.6, 25.6)* Change in concern score, mean (95% CI)^: 25.2 (22.8, 27.5)* Change in sleep, score, mean (95% CI)^: 21.9 (19.5, 24.3)* Change in social interaction score, mean (95% CI)^: 11.1 (9.4, 12.9)* Change in % work time missed, mean ± SD†: −1.84 ± 0.57 P = 0.0017 Change in % impairment while working, mean ± SD†: −11.64 ± 1.64 P < 0.0001 Change in % overall work impairment, mean ± SD †: −12.14 ± 1.79 P <0.0001 Change in % activity impairment, mean ± SD†: −13.21 ± 1.31 P < 0.001 Change in office visits, mean ± SD: −1.00 ± 0.08 P < 0.001 Change in UTI, mean ± SD: −0.12 ± 0.03 P < 0.001 Change in skin rash episodes, mean ± SD: −0.46 ± 0.34 P = 0.1801 Change in number of falls, mean ± SD: 0.04 ± 0.07 P = 0.5561 Change in number of pads/diapers/wk, mean ± SD: −2.79 ± 0.83 P = 0.0009 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: + Drop-out rates: NR Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +

^ gender accounted for in mixed-effects statistical model; * P = NS

Evidence Table 3 KQ2 Procedural and surgical treatments

Study Description | Study Design, Interventions, and Population | Inclusion/Exclusion Criteria | Symptom Characteristics | Outcomes | Quality Rating
Author: Enzelsberger et al. 1995 Country and setting: Austria, Academic gynecology/urology outpatient clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR | Design: RCT Intervention: Instillation of oxybutynin or sterile water into the bladder via a disposable catheter, administered over a period of 12 days Groups: G1: instillation of 20 mg oxybutynin in 40 mL sterile water G2: instillation of 40 mL sterile water N at enrollment: G1: 26 G2: 26 N at follow-up: G1: 23 G2: 20 Women, %: 100 Age, median (range): G1: 61 (55, 66) G2: 59 (56, 64) Race/ethnicity: NR Weight (kg), median (range): G1: 68 (58, 74) G2: 70 (59, 77) | Inclusion criteria: • Women • Presenting complaint of frequency (more than 5 times/12hr), nocturia (more than twice per night), and urgency • Confirmed idiopathic detrusor instability Exclusion criteria: • Urodynamically assessed genuine stress incontinence • Neurologic disorders | Daytime voids/day, median (range): G1: 7.5 (5, 15) G2: 8.2 (6, 12) Nocturia episodes/day, median (range): G1: 5.1 (3, 7) G2: 4.6 (3, 8) Voided volume (mL), first desire to void, median (range): G1: 95 (30, 140) G2: 90 (25, 170) Cystometric capacity (mL), median (range): G1: 205 (50, 340) G2: 195 (40, 260) Max pressure rise during filling (cmH_2_O), median (range): G1: 16 (10, 22) G2: 14 (9, 19) Max contraction (cmH_2_O), median (range): G1: 32 (20, 44) G2: 29 (18, 42) Peak flow rate (mL/s), median (range): G1: 27 (15, 45) G2: 30 (17, 40) Residual urinary volume (mL), median (range): G1: 40 (10, 50) G2: 35 (12, 50) Duration of symptoms (months), median (range): G1: 7 (2, 9) G2: 8 (3, 9) Previous operations for UI, n: G1: 11 G2: 10 | Daytime voids/day, median (range): G1: 4.0 (2, 7) G2: 6.9 (5, 10) P < 0.05 Nocturia episodes/day, median (range): G1: 1.8 (1, 3) G2: 3.5 (3, 6) P < 0.05 Voided volume (mL), first desire to void, median (range): G1: 150 (80, 180) G2: 110 (30, 140) P < 0.05 Cystometric capacity (mL), median (range: G1: 310 (100, 390) G2: 207 (43, 240) P < 0.05 Max pressure rise during filling (cmH_2_O), median (range): G1: 8 (5, 10) G2: 11 (6, 12) P < 0.05 Max contraction (cmH_2_O), median (range): G1: 14 (10, 20) G2: 24 (11, 42) P < 0.05 Peak flow rate (mL/s), median (range): G1: 22 (15, 40) G2: 32 (15, 45) Residual urinary volume (mL), median (range): G1: 81 (40, 140) G2: 38 (15, 60) P < 0.05 Dry mouth, n (%): G1: 4 (17) G2: 2 (10) Blurred vision, n (%): G1: 2 (8) G2: 1 (5) Nausea, n (%): G1: 0 G2: 0 Constipation, n (%): G1: 2 (8) G2: 3 (15) Dizziness, n (%): G1: 3 (13) G2: 0 Headache, n (%): G1: 1 (4) G2: 1 (5) UTI, n (%): G1: 4 (17) G2: 2 (10) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: − Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Fossberg et al., 1990 Country and setting: Norway, Denmark, Finland, Sweden, Academic medical center Enrollment period: NR Funding: NR Author industry relationship disclosures: NR | Design: Prospective case series Intervention: Treatment with a stimulation device including an anal and a vaginal plug electrode; stimulation provided at cyclic sweep within 5–10 Hz, administered 12 times for 20 minutes each (frequency of treatment not indicated) Groups: NA N at enrollment: 91 N at follow-up: 74 Women, %: 88 Age, mean (range): 53 (20–78) Race/ethnicity: NR Menopausal, %: 50 | Inclusion criteria: • Cystometrically proven detrusor instability, frequency and UUI Exclusion criteria: • UTI • Drugs affecting the lower urinary tract • Discontinued anticholinergic drugs < 6 weeks before study | Voids/day, mean ± SD (range): 9.1 ± 3.5 (4–20) Nocturia episodes/day, mean ± SD (range): 1.6 ± 1.1 (0–6) Bladder volume (mL), mean ± SD (range): 169 ± 68 (50–425) Bladder volume (mL), first sensation, mean ± SD (range): 139 ± 81 (33–300) Max cystometric capacity (mL), mean ± SD (range): 270 ± 155 (25–750) Previously treated with drugs for UUI, % 67 | Voids/day, before last treatment, mean ± SD (range): 7.9 ± 2.9 (3–18) P = 0.001 Voids/day, 6 weeks after last treatment, mean ± SD (range): 8.0 ± 2.8 (3–19) P = 0.003 Nocturia epsides/day, before last treatment, mean ± SD (range): 1.2 ± 1.2 (0–6) P = 0.002 Nocturia epsides/day, 6 weeks after last treatment, mean ± SD (range): 1.1 ± 1.1 (0–4) P < 0.001 Bladder volume (mL), before last treatment, mean ± SD (range): 189 ± 82 (50–490) P = 0.002 Bladder volume (mL), 6 weeks after last treatment, mean ± SD (range): 194 ± 93 (50–500) P < 0.001 Bladder volume (mL), first sensation, before last treatment, mean ± SD (range): 164 ± 93 (35–410) P = 0.008 Bladder volume (mL), first sensation, 6 weeks after last treatment, mean ± SD (range): 175 ± 114 (25–470) P = 0.003 Max cystometric capacity (mL), before last treatment, mean ± SD (range): 307 ± 159 (50–725) P = 0.009 Max cystometric capacity (mL), before last treatment, mean ± SD (range): 299 ± 174 (25–690) P = 0.12 Patient evaluation of effect, before last treatment, n: Cured: 6 Improved: 45 Unchanged: 23 Worse: 0 P < 0.001 Patient evaluation of effect, 6 weeks after last treatment, n: Cured: 8 Improved: 32 Unchanged: 34 Worse: 0 P < 0.001 Adverse effects, n:* 11 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: + Drop-out rates: − Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Groenendijk et al. 2007 [See evidence table for Hassouna et al. 2000] Country and setting: US, Canada, and Europe;16 centers Enrollment period: NR Funding: Medtronic Inc. Author conflict of interest: Medtronic (6) | Design: Cohort Intervention: implantable Interstim system stimulating the nerve ramus in preoperatively tested sacral nerve foramen Groups: G1: urge incontinence and detrusor overactivity (DO) G2: urge incontinence without detrusor overactivity N at enrollment: G1: 67 G2: 44 N at follow-up: G1: 51 G2: 32 Age: NR Race/ethnicity: NR Women, n: G1: 59 G2: 40 Follow-up: 6 months | Inclusion criteria: • >16 years of age • refractory to standard medical therapy • Bladder capacity of at least 100mL • -Normal upper urinary tract Exclusion criteria: • Treatable etiologies for urinary/frequency symptoms • Neurologic conditions • -Primary stress incontinence • Pelvic pain symptoms | First sensation of filling, mL ± SD: Overall: 82.8 ± 64.7 G1: NR G2: 122.2 ±78.8 Bladder volume at first detrusor contraction, mL ± SD: Overall: 104.7 ± 111.0 Bladder capacity, mL ± SD: Overall: 254 ± 138 G1: NR G2: 313 ± 117 Detrusor pressure at capacity, cm water ± SD: Overall: 27.7 ± 21.6 | First sensation of filling, mL ± SD: Overall: 167.4 ± 109.3, p<0.001 G1: NR G2: 192.4 ± 118.4 p=0.001 Bladder volume at first detrusor contraction, mL ± SD: Overall:133.7 ± 125.9, p =0.30 Bladder capacity, mL ± SD: Overall: 328 ± 148, p=0.001 G1: NR G2: 365 ± 115, p=0.02 Detrusor pressure at capacity, cm water ± SD: Overall: 17.7 ± 16.5 DO at 6 months, n (%): G1: −25 (49%) -stimulation was clinically successful in 19 (40%) -failed in 3 (6%) − 26 (51%) were negative for DO -stimulation was clinically successful in 20 (42%) - failed in 6 (12%) G2: −3 (9%)were positive for DO -stimulation was clinically successful in 2 (7%) - failed in 1 (4%) − 29 remained negative for DO -stimulation was successful in 23 (82%) -failed in 2 (7%) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: − Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: −, NR Baseline OAB status: + Baseline characteristics: − Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Hassouna et al., 2000 Country and setting: US, Canada, and Europe, 12centers Enrollment period: Ended June 1998 Funding: Medtronic Inc. Author conflict of interest: Medtronic | Design: Prospective cohort Intervention: implantable Interstim system stimulating the nerve ramus in preoperatively tested sacral nerve foramen Groups: G1: Neurostimulation G2: control N at enrollment: G1: 25 G2: 26 N at follow-up: 51 patients with urgency/frequency Age, mean yrs ± SD: Total: 39.0 ±11.8 Race/ethnicity: NR Women, %: 90 Follow-up: 6 months | Inclusion criteria: • >16 years of age • refractory to standard medical therapy • Bladder capacity of at least 100mL • -Normal upper urinary tract Exclusion criteria: • Treatable etiologies for urinary/frequency symptoms • Neurologic conditions • -Primary stress incontinence • Pelvic pain symptoms | Mean voids/day: 16.0 ±8.2 Mean mL voided/void: G1: 118±74 G2: 124±66 Mean max. voided volume: 288 ±156 Mean total voided volume/day: 1693± 866 Mean % indicating they felt empty: 44 ±39 Mean duration of urinary symptoms before enrollment: 8.1 ± 9.2 years Mean pelvic/bladder discomfort (0 none-3 severe): 2.1 ±0.8 Degree urgency before voiding: G1: 2.2±0.6 G2: 2.4±0.5 | Mean mL voided/void: G1: 226±124 G2: 123±75 P< 0.001 Degree urgency before voiding: G1: 1.6±0.9 G2: 2.3±0.5 P = 0.01 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: − Pt selection criteria: + Loss to followup: NR Drop-out rates: NR Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Janknegt et al., 2001 Country and setting: 15 investigators in US, Canada, and Europe Enrollment period: December 1993–September 1999 Funding: NR. Author conflict of interest: NR | Design: Prospective case series Intervention: implantable Interstim system stimulating the nerve ramus in preoperatively tested sacral nerve foramen Groups: NA N at enrollment: NA N at follow-up: 96 patients with urge incontinence Age: NR Women, n (%): 85 (89) Race/ethnicity: NR Follow-up: ≥12 months Mean follow-up 30.8 months (range 12–60) | Inclusion criteria: • age > 16 years • refractory to standard medical therapy for UUI • 100 mL bladder capacity with normal upper urinary tract Exclusion criteria: • neurological conditions • stress urinary incontinence • rimary pelvic pain | Duration of symptoms, mean yrs ± SD: 9.1± 7.0. Leaking episodes/day: 10.9 ±6.5 Leak severity ranking: 2.0 ±0.6 Absorbent pad/diapers replaced/day: 6.6 ±5.2 Pads/diapers used daily, mean ± SD: 7.1 ± 5.1 Leaking episodes per day, mean ± SD: 8.0± 4.8 Heavy leaks per day, mean ± SD: 4.7 ± 4.2 | Leaking episodes/day: 4.2 ± 4.9 p<0.0001 Completely dry, n (%): 25 (26) > 50% reduction in frequency of incontinent episodes, n (%): 35 (36) Leak severity ranking: 1.7±0.6 P<0.0001 Pads/diapers used daily mean ± SD: 2.9 ± 3.8 P<0.0001 Stopped using pads, n (%): 30 (33) Reduced pad use ≥ 50%, n (%): 25 (28) Heavy leaks per day, mean ± SD: 2.8± 4.0 P<0.0001 Eliminated both moderate and heavy leaking episodes, n (%): 38 (43) ≥ 50% reduction in moderate/heavy leaking, n (%): 18 (20) 11 patients explanted due to lack of efficacy (n=9), chronic leg pain (n=1), or bowel dysfunction (n=1) | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: ++ Drop-out rates: + Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Kessler et al., 2007 Country and setting: Switzerland, Swiss Registry database Enrollment period: July 2000 to December 2005 Funding: not described Author conflict of interest: Authors Kessler, Buchser, and Burkhard have consultancy agreements with Medtronic; author Zrehen is a Medtronic employee; Metronic Switzerland was assigned to monitor and maintain the Swiss Registry. | Design: Prospective case series Intervention: SNM testing and IPG implantation Groups: A portion of this series is composed of patients with urge incontinence (not further defined). N at enrollment: 209 evaluated: 181 female, 28 male. N at follow-up: 209: all evaluated were considered for adverse events of SNM testing 102 successful tests 91 had implantation of implantable pulse generator (IPG). 71 of these had urge incontinence. Age, median: 58 yrs Race/ethnicity: NR Follow-up, mean: 24 months for UUI | Inclusion criteria: • Tested for urge incontinence, nonobstructive chronic urinary retrention and chronic pain syndrome • Refractory to conventional therapies • Underwent urologic evaluation with medical history, physical exam, bladder and/or pain diary, urine analysis, urine culture and urodynamic studies before SNM. Exclusion criteria: NR | Urge incontinence, n: Female: 137 Male: 16 Leakages per 24 hrs, median: 5 Pads used per 24 hrs, median: 4 Voids per 24 hrs, median: 10 Of 91 who underwent IPG implantation (11 of the 102 with successful testing refused implantation): 71 urge incontinence; 13 nonobstructive chronic urinary retention and 7 chronic pelvic pain syndrome. | Median follow-up was 24 months. Primary outcome: subjective symptom improvement, changes in bladder/pain diary variables. SNM was considered successful in 64 of 91 implanted patients, including 50 with urge incontinence. This group at last follow-up had a median of 0 leakages per 24 hours, 1 pad use per 24 hours, 6 voids per 24 hours, and 80% subjective symptom improvement. Secondary outcome: Incidence and treatment of adverse events due to SNM: Adverse events were reported in 12 of 209 patients who were initially tested, including lead migration in 9, wound infection in 2, and refractory pain at tined lead site in 1. These were not broken down separately for urge incontinence group. Adverse events with IPG implantation were reported in 10 of 91 patients, including lead migration (2) broken lead (1), wound infection at IPG site (2), pain at IPG site (3), IPG migration (1), and IPG malfunction after MIR (1). 6 of these patients required surgical revision. These were not broken down separately for urge incontinence group. | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: ++ Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: − Measurement reliability: − Intervention description: +
Author: Koldewijn et al. 1994 Country and setting: The Netherlands Enrollment period: June 1990 to August 1993 Funding: NR | Design: Prospective case series Intervention: percutaneous stimulation of the sacral root S3 on the left and right sides Groups: NA N at enrollment: NR N at follow-up: 100 Age (mean): 42 years Women, n: 86 Race/ethnicity: NR | Inclusion criteria: • failed previous treatment with medication, behavioral therapy, surgery, or combination therapy Exclusion criteria: • No other lower urinary tract conditions | Urge incontinence, n: 46 Incomplete bladder emptying, n: 23 Urgency and frequency, n: 13 Mixed incontinence, n: 10 Dysuria or pelvic pain, n: 5 Stress incontinence, n: 3 Detrusor overactivity, n: 52 Detrusor underactivity, n : 24 Urethral instability, n: 5 No abnormalities by UDS, n: 19 No neuro-physiological abnormalities, n: 18 Central neuro-physiological abnormality, n: 10 Peripheral neuro-physiological abnormaility, n: 16 | Perfect improvement (>90%), n: 22 Moderate improvement (50–90 %), n : 8 Slight improvement (10–50%), n : 10 No response, n: 17 Pain in the area of puncture during stimulation, n: 7 | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: NR Drop-out rates: NR Power calculation: − Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: − Measurement methods: + Measurement reliability: − Intervention description: +
Author: Korda et al., 1987 Country and setting: Australia Enrollment period: 1983 – 1984 Funding: NR | Design: Prospective case series Intervention: Bladder distention Groups: NA N at enrollment: 50 N at follow-up: 50 Age: NR Race/ethnicity: NR Gender: 100% F Follow-up: 3, 6 and 12 mo | Inclusion criteria: • Diagnosis with detrusor instability and failure to respond to anticholinergic treatment Exclusion criteria: NR | NR | Extraperitoneal rupture: 2 patients At 3 mos: Symptom free: 10 Improved: 25 Unchanged: 15 At 12 mos: Symptom free: 9 Improved: 15 Unchanged: 26 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: − Loss to followup: ++ Drop-out rates: + Power calculation: − Statistical issues: − EXTERNAL VALIDITY: poor Age: −, NR Baseline OAB status: NR Baseline characteristics: − Length of followup: ++ Measurement methods: − Measurement reliability: − Intervention description: +
Author: Mundy 1983 Country and setting: UK Enrollment period: NR Funding: NR | Design: retrospective case series Intervention: bladder transection Groups, N: G1: 23; circumferential transection of the bladder wall just above the ureteric orifices G2: 81; transection of the posterior and posterolateral bladder wall from 1 cm lateral to the right ureteric orifice to 1 cm lateral on the left side ureteric orifice N at enrollment: 104 Duration of follow-up: at least 12 months (range 12–59 months; mean 35 months) N at follow-up: 104 at year 1, 82 at year 2, 49 at year 3, 25 at year 4, and 6 at year 5 Age mean yrs (range): 37 (19–81) Women, n (%): 91(87.5%) Race/ethnicity: NR No separate analysis by gender | Inclusion criteria: • urodynamically proven detrusor instability • frequency, urgency and urge incontinence for at least 3 years • failure to respond to standard conservative treatment (e.g. bladder drill, probanthine therapy, imipramine therapy, emepromium bromide therapy, hydrostatic bladder dilatation, oxybutynin) Exclusion criteria: NR | NR | Initial post-operative evaluation (3–6 months after operation): 74% cured, 14% improved; 12% failures; authors note same results at year 1 At last evaluation (in patients followed for 2–5 years): 53 (65% still cured), 16 (19%) improved; 13 (16%) failures 9 participants with residual symptoms after operation later responded to other therapies Among 68 patients with at least one postoperative urodynamic study: 50 symptomatically cured; 14 of these reverted to stability and 26 showed a shift to the right of the urodynamic pattern 28 were failures or showed partial response; 8 were no longer unstable, and 14 remained the same as before their operation; authors note 6 with genuine stress incontinence were successfully managed by appropriate surgical treatment Adverse events: 1 patient developed persistent urine leak from her bladder requiring reoperation. • Urodynamic evidence of vesicoureteric reflux postoperatively that had not been observed pre-operatively in 14 patients; none were symptomatic or developed acute pyelonephritis | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: − Loss to followup: ++ Drop-out rates: + Power calculation: − Statistical issues: − EXTERNAL VALIDITY: poor Age: + Baseline OAB status: NR Baseline characteristics: − Length of followup: ++ Measurement methods: − Measurement reliability: − Intervention description: −
Author: O’Reilly et al., 2008 Country and setting: Australia, Academic health centers Enrollment period: NR Funding: NR Author industry relationship disclosures: NR | Design: RCT Intervention: Trans-sacral nerve (S3–S4) stimulation vs sham Groups: G1: transsacral nerve magnetic stimulator of the S3 and S4 nerve roots × 20 min/day × 12 wk G2: sham × 20 min/day × 12 wk N at enrollment: G1: 33 G2: 30 N at follow-up: G1: 33 G2: 30 Women, %: 100 Age, mean ± SD: G1: 62.6 ± 13.45 G2: 59.8 ± 14.19 | Inclusion criteria: •Women •Age ≥ 18 •Ability to give informed consent •Ability to comply w/instructions to use the device •Ability to perform treatment over an 84-d period and attend for f/u •OAB symptoms for ≥ 6 mos •Unresponsive to behavioral measures or anticholinergic medication Exclusion criteria: •Pregnancy •Actively trying to conceive •Waking voiding frequency < 7 in 12 hrs •Nocturia < 2 •SUI symptoms •Benign or malignant bladder tumor •UTI •Previous irradiation or drug-induced cystitis •Symptomatic diverticulum •Vaginal infection •DM •Peripheral neuropathy •Cardiovascular disease •Cancer of the genital tract, urinary tract calculi •Cardiac arrhythmia | Voids/day, mean ± SD G1: 10 ± 3.2 G2: 9 ± 3.3 Symptom impact, median VAS score (IQR): G1: 80 (50–90) G2: 80 (70–90) AQoL, overall mean score ± SD: G1: 0.67 ± 0.22 G2: 0.67 ± 0.26 AQoL, illness, median score (IQR): G1: 0.42 (0.14–0.87) G2: 0.40 (0.17–0.87) AQoL, independent living, median score (IQR): G1: 1 (0.87–1) G2: 1 (0.88–1) AQoL, social relationships, median score (IQR): G1: 1 (0.90–1) G2: 0.97 (0.79–1) AQoL, physical senses, median score (IQR): G1: 0.94 (0.86–1) G2: 0.97 (0.92–1) AQoL, psychological well-being, median score (IQR): G1: 0.85 (0.85–0.91) G2: 0.87 (0.85–0.93) KHQ, general health, median score (IQR): G1: 25 (0–25) G2: 25 (25–50) KHQ, incontinence Impact, median score (IQR): G1: 100 (66.6–100) G2: 100 (66.6–100) KHQ, role limitations, median score (IQR): G1: 66.6 (50–83.3) G2: 58 (33.3–83.3) KHQ, physical limitations, median score (IQR): G1: 50 (16.6–83.3) G2: 50 (16.6–66.6) KHQ, social limitations, median score (IQR): G1: 30 (10–70) G2: 30 (10–60) KHQ, personal relationships, median score (IQR): G1: 16.6 (0–66.6) G2: 16.6 (0–50) KHQ, emotions, median score (IQR): G1: 66.6 (33–100) G2: 55.2 (22.2–88.8) G2: 50 (33.3–83.3) KHQ, sleep and energy, median score (IQR): G1: 66.6 (33.3–83.3) KHQ, severity measures, median score (IQR): G1: 60 (46.6–76.6) G2: 50 (40–66.6) Voided volume (mL), median (IQR): G1: 350 (250–500) G2: 400 (300–550) Total voided volume/day (mL), mean ± SD: G1: 1850 ± 715 G2: 1800 ± 750 | Voids/day, mean ± SD: G1: 9 ± 2.7 G2: 9 ± 3.2 Symptom impact, median VAS score (IQR): G1: 70 (40–90) G2: 75 (50–80) AQoL, overall mean score ± SD: G1: 0.69 ± 0.22 G2: 0.72 ± 0.25 AQoL, illness, median score (IQR): G1: 0.52 (0.19–0.81) G2: 0.42 (0.17–0.87) AQoL, independent living, median score (IQR): G1: 1 (0.9–1) G2: 1 (0.83–1) AQoL, social relationships, median score (IQR): G1: 0.94 (0.88–1) G2: 0.94 (0.86–1) AQoL, physical senses, median score (IQR): G1: 0.94 (0.86–1) G2: 0.94 (0.92–1) AQoL, psychological well-being, median score (IQR): G1: 0.85 (0.83–0.93) G2: 0.90 (0.85–0.98) KHQ, general health, median score (IQR): G1: 25 (0–50) G2: 25 (0–50) KHQ, incontinence Impact, median score (IQR): G1: 100 (33.3–100) G2: 100 (33.3–100) KHQ, role limitations, median score (IQR): G1: 33.3 (16.6–83.3) G2: 33.3 (0–66.6) KHQ, physical limitations, median score (IQR): G1: 41.6 (16.6–83.3) G2: 50 (16.6–66.6) KHQ, social limitations, median score (IQR): G1: 25 (10–60) G2: 20 (10–30) KHQ, personal relationships, median score (IQR): G1: 0 (0–33.3) G2: 0 (0–33.3) KHQ, emotions, median score (IQR): G1: 44.4 (22.2–88.8) G2: 44.4 (22.2–77.7) KHQ, sleep and energy, median score (IQR): G1: 50 (33.3–66.6) G2: 50 (33.3–66.6) KHQ, severity measures, median score (IQR): G1: 53.3 (33.3–73.3) G2: 46.6 (40–66.6) Voided volume (mL), median (IQR): G1: 425 (250–550) G2: 375 (300–500) Total voided volume/day (mL), mean ± SD: G1: 1780 ± 630 G2: 1790 ± 710 | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: + Masking: + Pt selection criteria: + Loss to followup: ++ Drop-out rates: + Power calculation: + Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Rios et al., 2007 Country and setting: Brazil, academic hospital Enrollment period: NR Funding: Departments of Urology of the Federal University of São Paulo, Paulista School of Medicine and Hospital do Servidor Puìblico Estadual de São Paulo Author industry relationship disclosures: None | Design: RCT Intervention: intravesical resiniferatoxin (RTX) Groups: G1: single dose 100 ml 50 nM RTX G2: placebo N at enrollment: G1: 34 G2: 24 N at follow-up: G1: 33 G2: 23 Women, %: 100 Age, mean ± SD: 56 ± 12.09 Race/ethnicity: NR | Inclusion criteria: •Urinary frequency, daily urgency & UUI, nocturia for > 6 mos prior to study •Involuntary detrusor contractions on cystometrogram Exclusion criteria: •Use of anticholinergics or tricyclic antidepressants in last 2 mos •Neurologic conditions •UTI •Pelvic prolapse > grade 2 •History of pelvic radiation or bladder tumor •Poor bladder wall compliance •Detrusor underactivity | Incontinence episodes/day, per-protocol analysis, mean ± SD: G1: 3.11 ± 2.50 G2: 5.76 ± 3.39 P = 0.002 Incontinence episodes/day, ITT analysis, mean ± SD: G1: 3.00 ± 2.46 G2: 5.06 ± 3.37 P = 0.015 Voids/day, per-protocol analysis, mean ± SD: G1: 9.68 ± 2.92 G2: 9.94 ± 2.76 P = 0.756 Voids/day, ITT analysis, mean ± SD: G1: 9.66 ± 2.88 G2: 9.90 ± 2.58 P = 0.746 Enuretic episodes/wk, per-protocol analysis, mean ± SD: G1: 0.33 ± 0.53 G2: 0.59 ± 0.80 P = 0.340 Enuretic episodes/wk, ITT analysis, mean ± SD: G1: 0.36 ± 0.53 G2: 0.46 ± 0.72 P = 0.864 Nocturia episodes/day, per-protocol analysis, mean ± SD: G1: 2.22 ± 1.02 G2: 2.29 ± 1.26 P = 0.827 KHQ, sleep and energy, mean score ± SD: G1: 43.43 ± 26.66 G2: 37.50 ± 24.71 KHQ, symptom severity, mean score ± SD: G1: 8.08 ± 7.59 G2: 10.88 ± 13.55 Cystometric capacity, per-protocol analysis, mean ± SD: G1: 112.94 ± 68.22 G2: 124.15 ± 76.05 P = 0.581 Cystometric capacity, ITT analysis, mean ± SD: G1: 114.62 ± 67.89 G2: 127.42 ± 72.99 P = 0.496 Max cystometric capacity, per-protocol analysis, mean ± SD: G1: 285.8 ± 183.20 G2: 246.50 ± 92.87 P = 0.306 Max cystometric capacity, ITT analysis, mean ± SD: G1: 287.47 ± 180.64 G2: 240.63 ± 85.77 P = 0.194 Bladder volume, first involuntary contraction, per-protocol analysis, mean ± SD: G1: 89.31 ± 44.58 G2: 125.56 ± 79.92 P = 0.263 Bladder volume, 1st involuntary contraction, ITT analysis, mean ± SD: G1: 103.82 ± 59.51 G2: 124.38 ± 73.01 P = 0.243 Max detrusor voiding pressure, per-protocol analysis, mean ± SD: G1: 35.90 ± 12.05 G2: 34.06 ± 12.86 P = 0.807 Max detrusor voiding pressure, ITT, analysis, mean ± SD: G1: 33.59 ± 12.59 G2: 35.00 ± 11.67 P = 0.666 | Incontinence episodes/day, per- protocol analysis, mean ± SD: G1: 2.68 ± 3.08 G2: 4.50 ± 3.83 P = 0.012 Incontinence episodes/day, ITT analysis, mean ± SD: G1: 2.72 ± 3.04 G2: 4.20 ± 3.57 P = 0.027 Voids/day, per- protocol analysis, mean ± SD: G1: 9.03 ± 2.77 G2: 9.10 ± 2.68 P = 0.814 Voids/day, ITT analysis, mean ± SD: G1: 9.03 ± 2.73 G2: 9.21 ± 2.53 P = 0.738 Enuretic episoldes/wk, per-protocol analysis, mean ± SD: G1: 0.15 ± 0.34 G2: 0.65 ± 1.06 P = 0.140 Enuretic episodes/wk, ITT analysis, mean ± SD: G1: 0.17 ± 0.36 G2: 0.52 ± 0.98 P = 0.321 Nocturia episodes/day, per-protocol analysis, mean ± SD: G1: 1.73 ± 1.14 G2: 1.82 ± 1.16 P = 0.794 Nocturia episodes/day, ITT analysis, mean ± SD: G1: 2.21 ± 1.02 G2: 2.28 ± 1.19 P = 0.796 KHQ, general health perception, mean score ± SD: G1: 37.88 ± 14.14 G2: 42.70 ± 21.61 KHQ, incontinence impact, mean score ± SD: G1: 77.78 ± 28.46 G2: 83.33 ± 22.94 KHQ, role limitations, mean score ± SD: G1: 62.63 ± 36.33 G2: 70.00 ± 35.29 KHQ, physical limitations, mean score ± SD: G1: 59.60 ± 34.37 G2: 60.00 ± 31.71 KHQ, social limitations, mean score ± SD: G1: 27.44 ± 25.23 G2: 29.90 ± 28.64 G2/G1: P < 0.05 KHQ, personal relationship, mean score ± SD: G1: 34.92 ± 41.47 G2: 26.47 ± 34.89 KHQ, emotions, mean score ± SD: G1: 57.24 ± 35.59 G2: 66.11 ± 29.39Nocturia episodes/day, ITT analysis, mean ± SD: G1: 1.77 ± 1.14 G2: 1.89 ± 1.12 P = 0.769 KHQ, general health perception, mean score ± SD: G1: 34.85 ± 13.89 G2: 43.75 ± 24.16 KHQ, incontinence impact, mean score ± SD: G1: 60.61 ± 33.80 G2: 65.00 ± 38.20 G1/BL: P < 0.05 G2/BL: P < 0.05 KHQ, role limitations, mean score ± SD: G1: 48.99 ± 35.09 G2: 49.12 ± 37.46 G2/BL: P < 0.05 KHQ, physical limitations, mean score ± SD: G1: 45.45 ± 36.39** G2: 44.17 ± 39.84 KHQ, social limitations, mean score ± SD: G1: 21.55 ± 25.30 G2: 38.50 ± 31.91 KHQ, personal relationship, mean score ± SD: G1: 27.08 ± 38.33 G2: 37.50 ± 41.51 KHQ, emotions, mean score ± SD: G1: 42.76 ± 35.80 G2: 54.45 ± 37.10 G1/BL: P < 0.05 KHQ, sleep and energy, mean score ± SD: G1: 28.79 ± 24.03 G2: 38.33 ± 31.11 G1/BL: P < 0.05 KHQ, symptom severity, mean score ± SD: G1: 13.94 ± 9.91 G2: 10.88 ± 11.80 G1/BL: P < 0.05 Cystometric capacity, per-protocol analysis, mean ± SD: G1: 144.70 ± 93.41 G2: 172.75 ± 117.83 P = 0.310 Cystometric capacity, ITT analysis, mean ± SD: G1: 145.44 ± 92.08 G2: 167.92 ± 109.93 P = 0.322 Max cystometric capacity, per-protocol analysis, mean ± SD: G1: 298.03 ± 161.48 G2: 270.50 ± 109.57 P = 0.402 Max cystometric capacity, ITT analysis, mean ± SD: G1: 299.26 ± 159.18 G2: 260.63 ± 102.37 P = 0.237 Bladder volume, 1st involuntary contraction, per-protocol analysis, mean ± SD: G1: 120.17 ± 68.98 G2: 140.83 ± 84.34 P = 0.093 Bladder volume, 1st involuntary contraction, ITT analysis, mean ± SD: G1: 121.83 ± 68.39 G2: 139.09 ± 79.83 P = 0.102 Max detrusor voiding pressure, per-protocol analysis, mean ± SD: G1: 33.83 ± 15.78 G2: 32.33 ± 12.29 P = 0.625 Max detrusor voiding pressure, ITT analysis, mean ± SD: G1: 33.33 ± 15.74 G2: 32.91 ± 11.50 P = 0.819 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: − Masking: + Pt selection criteria: − Loss to followup: ++ Drop-out rates: NR Power calculation: − Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Schmid et al. 2006 Country and setting: Switzerland; 3 clinics Enrollment period: January 2003 to October 2004 Funding: International Institute for Research in Paraplegia; Swiss National Science Foundation Author conflict of interest: NR | Design: prospective case series Intervention: 1000 U Botox-A in 10 mL 0.9% normal saline injected into the detrusor muscle 1–2 mm under the urothelium layer at 30 sites on the inner surface of the bladder wall (approx. 0.3 mL each injection) Groups: NA N at enrollment: 100 N at follow-up: 100 at 1 month; 80 at 3 months; 20 at 9 months Age: mean 63 years (range 24–89) Race/ethnicity: NR Follow-up: patients followed 4, 12, and 36 weeks after treatment Mean follow-up: 20 weeks (range 4–36) No separate analysis by gender | Inclusion criteria: • OAB syndrome (ICS) • Urodynamically demonstrable nonneurogenic detrusor overactivity or hypersensitive bladder with premature filling sensation • ≥ 8 voids per 24 hours (with or without incontinence) • Not effectively treated with maximal doses of anticholinergics (or unable to tolerate those drugs) Exclusion criteria: • Renal dysfunction • Myasthenia gravis • Neurogenic bladder dysfunction • Serious illness • Pregnant or breastfeeding • Interstitial cystitis • Radiocystitis • Bladder tumor • Chronic pelvic pain syndrome • Prostate hyperplasia • Infravesical obstruction • PVR > 150 mL • Hypocontractile/acontractile detrusor • Prior SUI surgery and de novo urge • Mixed incontinence | Maximal cystometric bladder capacity (mL; mean ± SD): 246 ±15 Detrusor compliance (mL/cm H2O; mean ± SD): 24.5 ± 2.3 Reflex volume (mL; mean ± SD): 169 ±14 (n=54) First desire to void (mL mean ± SD): 125 ±13 Urgency to void (mL; mean ± SD): 214 ±16 Postvoid residual (mL; mean ± SD): 21 ±8 Incontinence, n: 84 Voiding frequency/24 hrs, n: 9–15 times: 37 16–23 times:41 >24 times: 24 | Voiding frequency/24 hrs: 4–8 times: 69 8–15 time: 24 Maximal cystometric bladder capacity (mL; mean ± SD): 1 mo.: 381 ±19 3 mos.: 384 ±19 9 mos.: 325 ±55 Detrusor compliance (mL/cm H2O; mean ± SD): 1 mo.: 40.5 ±2.9 3 mos.: 45.1 ±2.9 9 mos.: 37.1 ±8.4 Reflex volume (mL; mean ± SD): 1 mo.: 229 ±25 (n=14) 3 mos.: 222 ±35 (n=14) 9 mos.: 195 ±57 (n=6) First desire to void (mL mean ± SD): 1 mo.: 212 ±16 3 mos.: 208 ±16 9 mos.: 178 ±40 Urgency to void (mL; mean ± SD): 1 mo.: 309 ±20 3 mos: 332 ±20 9 mos: 210 ±57 Postvoid residual (mL; mean ± SD): 1 mo: 75 ±10 3 mos: 85 ±10 9 mos: 14 ±28 • Urgency disappeared in 72 patients at the 4 week assessment and in 66% at the 12 week followup • Incontinence disappeared in 74% at 4 week follow-up and 80% at 12 week followup • No improvement in 8 patients • 90% of patients experienced improvement in at least 1 quality of life category, increasing at 3 month follow-up and decreasing at 9 months Adverse events: • 4 patients developed temporary (4 week) urinary retention and postvoid residual > 400 mL at 1–2 weeks after injection, requiring temporary intermittent clean self-catheterization; PVR returned to baseline within 6–9 months • 15 patients reported mild difficulty in voiding during the first moth with PVR 150–200 mL; declined ICSC • 10 patients developed bladder infection successfully treated by antibiotics | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: + Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Schmidt et al., 1999 Country and setting: 16 centers in US, Canada, and Europe Enrollment period: 1993- April 1997 Funding: Supported by Medtronics Inc. Author conflict of interest: Schmidt, Jonas, Oleson, Janknegt, Siegel: financial interest and/or other relationship with Medtronic Inc. | Design: randomized controlled trial Intervention: implantable Interstim system stimulating the nerve ramus in preoperatively tested sacral nerve foramen Groups: G1: implantation with immediate stimulation (n=34 for efficacy analysis) G2: control group receiving standard medical therapy for 6 months; allowed to cross over at 6 months if remained eligible for implantation (n=42 for efficacy analysis) N at enrollment: 155 N randomized: 98 (the remaining 57 did not respond to test stimulation so were not randomized) N at follow-up: 76 at 6 months Age: mean 46.6 ±13.0 (range 20.2 – 78.9) Gender: 125 F (80.6%), 30 M (19.4%) Race/ethnicity: NR | Inclusion criteria: • age > 16 years • refractory to standard medical therapy • ≥ 100 mL bladder capacdity with normal upper urinary tract • good surgical candidate • able to complete study documentation and return for follow-up evaluation Exclusion criteria: • neurological conditions • stress urinary incontinence • primary pelvic pain | Duration of urinary symptoms before enrollment: mean 9.0±7.4 (range 0.6–35.4) Mean number of daily incontinence episodes: 8.9± 5.9 G1: 9.7 ± 6.3 G2: 9.3 ± 4.8 Mean leak severity rating: 1.9± 0.6 G1: 2.0 ± 0.7 G2: 1.8 ± 0.6 Mean absorbent pads/diapers replaced daily 4.8± 4.8 G1: 6.2 ± 5.0 G2: 5.0 ± 3.7 Mean heavy incontinence episodes per day: G1: 3.4 ±3.8 G2: 2.6 ±3.5 3-day diary data: 90.3% of patients had at least 1 moderate/heavy and 74.8% had at least 1 heavy incontinence episode Previous treatment for urinary problems: 153 (89.7%), including pharmacological in 144 (92.5%, nonsurgical in 55 (35.5%), and surgical in 88 (56.8%) | At 6 months: Mean number of daily incontinence episodes: G1: 2.6± 5.1 (p<0.0001) G2: 11.3 ± 5.9 (p=0.002) Mean leak severity rating: G1: 0.8 ± 0.9 (p<0.0001) G2: 2.0± 0.6 (p=0.006) Mean absorbent pads/diapers replaced daily G1: 1.1 ± 2.0 (p<0.0001) G2: 6.3 ± 3.6 (p=0.003) Mean heavy incontinence episodes per day: G1: 0.3 ±0.9 (P<0.0001) G2: 3.9 ±3.8 G1: 47% completely dry at 6 months; 3 patients had no reduction in incontinence after 6 months (one underwent device explantation and 2 had increased frequency of urination and incontinence) Safety data (pooled for 157 patients): adverse events requiring surgical repositioning or replacement of implant devices document in 51 (32.5%) 168 post-implant events reported by 83 patients, including pain at the neurostimulator site in 15.9%, pain at implant site in 19.1, and lead migration in 7.0% Infection or skin irritation led to device explantation in 2 patients and templorary explant in 2 patients No permanent injuries or nerve damage reported. | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: minus; Pt selection criteria: + Loss to followup: minus; Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Siegel et al. 2000 Country and setting: US, Canada, and Europe, 12 centers in Enrollment period: 1993– 999 Funding: partially funded through restricted research grants from Medtronics Inc. Author conflict of interest: NR | Design: case series Intervention: implantable Interstim system stimulating the nerve ramus in preoperatively tested sacral nerve foramen N at enrollment: 219 undergoing stimulator placement (from pool of 581 patients evaluated)* UUI: urge incontinence (n=41) Urgency/Frequency: (n=29) N at follow-up: total=112; 23 additional patients had undergone device explantation and an additional 84 were not yet due for long-term follow-up Age, mean (range): 43 (17–81) Women, %: 78% Race/ethnicity: NR | Inclusion criteria: • patients who received implanted Interstim and were due for long-term follow-up Exclusion criteria: NA Indications, N: Urge incontinence: 41 Urgency/frequency: 29 Retention: 42 | UUI episodes/day, mean ± SD: 11.6 ± 6.6 Heavy episodes per day, mean ± SD: 3.6 ±4.0 Pads per day, mean ± SD: 6.7 ±4.6 Voids per day: 17.7 ±8.6 Average volume per void: 132.5 ±93.6 Average degree of urgency before voiding (scale 1 mild − 3 severe): 2.2. ±0.7 Void volume per void, mean mL ± SD: 343 ± 167 | UUI episodes/day, mean ± SD: 5.0 ±6.1 P<0.0001 Heavy episodes per day, mean ± SD: 1.3 ±3.5 P<0.0001 Pads per day, mean ± SD: 3.4 ±4.9 P<0.0001 Voids per day: 10.6 ±6.6 P < 0.0001 Void volume per void, mean mL ± SD: 225 ±162 P < 0.0001 Improvement in degree of urgency before voiding was present in 69% of patients Eliminated use of catheterization, %: 58 Adverse events: Pain at neurostimulator site (15.4%), new pain (9.0%), suspected lead migration (8.4%), infection (6.1%), transient electric shock (5.5%), pain at lead site (5.4%), adverse change in bowel function (3.0%), technical problems (1.7%), suspected device problems (1.6%), change in menstrual cycle (1.0%), adverse change in voiding function (0.6%), persistent skin irritation (0.5%), suspected nerve injury (0.5%), device rejection (0.5%), other (9.5%) Surgical revision rate: 33% (73/219) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: − Loss to followup: − Drop-out rates: − Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Spinelli et al., 2001 Country and setting: Italy, Registry Enrollment period: NR Funding: NR Author industry relationship disclosures: NR | Design: Case series Intervention: sacral neuromodulation with Itrel II or Interstim stimulation system Groups: G1: retrospective cases G2: prospective cases N at enrollment: G1: 93 G2: 103 N at follow-up: G1: 65 G2: NR Age, mean (range): G1: 50.9 (17, 79) G2: 50.1 (17, 79) Race/ethnicity: NR Women, %: G1: 80.6 G2: 72.8 Follow-up: G1: median 40 months, range 28–73 months G2: 3, 6, 9, 12, 18 and 24 months | Inclusion criteria: • placement of a sacral neurostimulator Exclusion criteria: NR | Incontinence episodes/day, mean ± SD: G2: 5.4 ± 3.9 Detrusor instability QoL index, mean: G2: 33.1 Urgency/frequency QoL index, mean: G2: 40 Detrusor instability, n (%): G1: 44 (47.3) G2: 42 (40.8) Retention, n (%): G1: 20 (21.5) G2: 25 (24.3) Neurogenic retention, n (%): G1: 0 G2: 10 (9.7) Detrusor hyperreflexia, n (%): G1: 8 (8.6) G2: 15 (14.6) Urgency/frequency, n (%): G1: 5 (5.6) G2: 5 (4.9) Pelvic pain, n (%): G1: 9 (9.7) G2: 4 (3.9) Urethral instability, n (%): G1: 4 (4.3) G2: 2 (1.9) Interstitial cystitis, n (%): G1: 3 (3.2) G2: 0 Detrusor instability or urgency/frequency, n (%): Total: 102 (52) | Mean incontinence episodes/day, UUI patients (including detrusor or urethral instability), %: Completely dry: G1: 39 < 1 episode: G1: 23 1–3 esisodes: G1: 23 > 3 episodes: G1: 15 Incontinence episodes/day, 12 mo, mean ± SD: G2: 1.1 ± 1.6 P < 0.001 Completely dry, 3 months, %: G2: 57 P = NR Completely dry, 6 months, %: : G2: 65 P < 0.001 Completely dry, 9 months, %: G2: 55 P < 0.003 Completely dry, 12 months, %: G2: 59 P < 0.001 Completely dry, 18 months, %: G2: 43 P < 0.04 Mean voids/day, %: < 8 voids: G1: 42 8–12 voids: G1: 42 >12 voids: G1: 18 Detrusor instability QoL index, 3 months, mean: G2: 74.7 P < 0.001 Detrusor instability QoL index, 6 months, mean: G2: 80.5 P < 0.001 Detrusor instability QoL index, 12 months, mean: G2: 69.6 P < 0.001 Detrusor instability QoL index, 18 months, mean: G2: 73.7 P = NR Urgency/frequency QoL index, 3 months, mean: G2: 73 P = NR Urgency/frequency QoL index, 6 months, mean: G2: 66 P = NS Urgency/frequency QoL index, 12 months, mean: : G2: 69.5 P = NS Not requiring catheterization (but baseline catheterization), 3 months, %: G2: 67 P < 0.001 Not requiring catheterization (but baseline catheterization), 6 months, %: G2: 67 P < 0.001 Not requiring catheterization (but baseline catheterization), 9 months, %: G2: 50 P < 0.001 Not requiring catheterization (but baseline catheterization), 12 months, %: G2: 50 P < 0.003 Any adverse events, %: G1: NR G2: 15.5 Pain at implant site or extension cable connector, %: G2: 3.9 Hematoma/wound problem, %: G2: 1.9 Surgical revision necessary, %: G2: 9.7 Lead fracture, %: G2: 3.9 Explant of stimulation system, %: G2: 3.9 Lead repositioning, %: G2: 1.9 Lead displacement, %: G1: 6.5 New lead required due to initial bad position, %: G1: 3.2 Explantation of pulse generator due to infection, %: G1: 1 Lead breakage, %: G1: 1 System removed due to treatment failure, %: G1: 3.2 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: − Loss to followup: + Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: + Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Sutherland et al. 2007 Country and setting: US continence and female urology clinic Enrollment period: December 1993 to December 2004 Funding: funded in part by Medtronic, Inc. Author conflict of interest: 3 authors received fees for educational speaking on OAB and incontinence from Pfizer, Indevus, Astellas, and Medtronic, and consulting fees from Medtronic | Design: retrospective case series Intervention: implantable pulse generator for sacral nerve stimulation (device made by Medtronic) N at enrollment: 234 patients underwent the procedure N at follow-up: 104 patients were consented Age, mean yrs ± SD: 50 ± 13.4 Women, N: 91 Race/ethnicity: NR Gender: Mean follow-up 22 months (range 3–162 months) | Inclusion criteria: • Undergoing SNS Exclusion criteria: NR | Voids per 24 hrs, mean ± SD: 12.4 ±5.1 Nocturnal voids per 24 hrs, mean ± SD: 2.3 ±1.8 Leaks per 24 hrs, mean ± SD: 5.0 ±4.7 Pads used per 24 hrs, mean ± SD: 2.3 ±2.6 Duration of symptoms, mean mos (range): 116–130 (9–600) | Urge incontinence: 96% experienced reduction in pad use after SNS therapy; 50% completely dry; 46% used fewer pads, and 4% had no change Voids per 24 hrs, mean ± SD: 8.5 ±5.0 voids/24 hr P < 0.0001 Nocturnal voids per 24 hrs, mean ± SD: 1.6 ±2.2 P = 0.0091 Leaks per 24 hrs, mean ± SD: 1.0 ±1.4 leaks/24 hr P < 0.0001 Pads used per 24 hrs, mean ± SD: 0.3 ±0.7 pads/24 hr P < 0.0001 Subjective improvement: >50%: 69% >80%: 50% >90%: 35% Satisfaction: - satisfied: 60.5% - equivocal: 23.3% - dissatisfied: 16.1% Adverse events: - infection: 13 events (4 severe requiring hospitalization for iv antibiotics) - hematoma: 2 events - discomfort at component: 28 events battery depletion: 5 events - bowel complaints: 4 events - pelvic pain: 1 event - high impedance: 2 events - malposition of component: 1 event - seizures: 2 events - herpes flare: 3 events | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Method and blinding: NA Pt selection criteria: + Loss to followup: − Drop-out rates: NA Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: + Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: van Kerrebroeck et al., 2007 Country and setting: US, Canada, and Europe, 17 centers Enrollment period: NR Funding: Medtronic Inc. Author conflict of interest: authors have financial interest and/or other relationship with Medtronic and other pharma and device companies (AMS, Astellas, Pfizer, Advanced Bionics, Uroplasty, Uromedica, J&J, Novartis, UCB, Bayer, Boehringer, Allergan, BioXell SpA, Alza, Solvay Pharma, Lilly Icos, Sanofi-Synthelabo, Janssen-Ortho, Purde Pharma, Negma Lerad, Laserscope, QLT, Lumenis, Schwarz, Glaxo, Eli Lilly, Boston Scientific) | Design: Prospective case series Intervention: implantable Interstim system stimulating the nerve ramus in preoperatively tested sacral nerve foramen N at enrollment: 163; 152 with implants N at follow-up, 1 year 79 Age mean ± SD: 44.7 ± 11.2 Women, n (%): 141 (87) Race/ethnicity: NR | Inclusion criteria: • patients receiving Interstim for management of voiding dysfunction Exclusion criteria: NR | UUI: -average number of leaking episodes per day: 9.6 ±6.0 - number of heavy leaks per day: 2.6± 3.3 - number of pads per day: >5 Frequency: - average number of voids per day 19.3±7.0 - average voided volume (mL): 92.3±52.8 -degree of urgency/day: 2.3±0.6 Urinary frequency: 28 UUI: 87 Urinary retention: 31 * | UUI: -average number of leaking episodes per day: 4.7 ±4.9 at one year follow-up; maintained throughout follow-up with mean 3.9± 4.0 at 5 years - number of heavy leaks per day: 1.2± 2.7 at one year follow-up and 0.8± 1.7 at 5 year follow-up - number of pads per day: 1.8 at 5 years follow-up Frequency: - average number of voids per day 13.0±7.9 at year 1 and 14.8± 7.6 at year 5 - average voided volume (mL): 169.9±118.2 at year 1 and 165.2± 147.7 at year 5 -degree of urgency/day: 1.9±0.8 at year 1, 2.1±0.7 at year 5 Adverse events: -110 events required surgery in 60 patients - system explanted from 16 due to AE or lack of efficacy - 31 AEs were device related and 240 were therapy related - new pain or undesirable change in stimulation: 43 patients, 60 events Pain at PNE or implant site, INS: 30 patients, 40 events -infection at PNE or implant site: 12 patients, 14 events - pain at PNE or implant site, lead: 12 patients, 13 events - sensation of electric shock: 12 patients, 14 events - undesirable change in voiding function 11 patients, 12 events - lead migration: 13 patients, 14 events - technical problems during PNE/implant: 8 patients, 8 events - device problem: 16 patients, 19 events - Other: 51 patients, 77 events -surgical intervention required for adverse events in 60 patients (110 events), including device exchange in 36 patients, positioning of pulse generator in 12, reposition of lead and generator in 10, reposition lead in 10, permanent explant in 9, temporary explant in 2, other intervention in 2, bilateral implant in 1, and surgical wound care in 1 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: ++ Drop-out rates: + Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: van Voskuilen et al., 2006 Country and setting: Netherlands, academic medical center Enrollment period: 1990 to 2003 Funding: WAMU Foundation Author industry relationship disclosures: NR | Design: retrospective case series Intervention: sacral nerve stimulation with Itrel-I device (1990 – 1994), Itrel-II device (1994 – 1999), or Interstim device (1999-2003) Groups: NA N at enrollment: 190 N at follow-up: 149 Women, n (%): 122 (81.9) Age, mean yrs ± SD: 46.7 (10.0) Race/ethnicity: NR Follow-up, mean mos ± SD: 64.2 (38.5) | Inclusion criteria: • Receiving a neuromodulation system or revision surgery for urge incontinence or urgency-frequency (with or without pelvic pain complaints), or non-obstructive urinary retention Exclusion criteria: • Percutaneous tined lead procedure • Receiving bilateral stimulation | Overactive bladder, n (%): 107 (71.8) Urinary retention, n (%): 42 (28.2%) Idiopathic urgency/frequency or retention, n (%): 129 (86.6%) Neurologic urgency/frequency or retention: 42 (28.2%) | Good result, n (%): 89 (59.7) Insufficient results, n (%): 44 (29.5) Reprogramming session at last visit, n (%): 16 (10.7%) Good result after reprogramming, n (%): 11 (68.8) Insufficient results after reprogramming, n (%): 5 (31.3) Adverse events, n: 194 in 106 patients Pain/undesirable change in stimulation, n: 64 Undesirable change in voiding function/loss of efficacy, n: 42 Pain at IPG implant site, n: 41 Adverse change in bowel function, n: 15 Suspected lead migration, n: 10 Suspected device problem (including lead breakage), n: 6 Infection, n: 6 Technical problem, n: 5 Suspected neuropraxia, n: 2 Other, n: 3 Requiring at least one reoperation due to AE, %: 48.3 Life span of replaced IPGs, mean mos (range): 73.7 (28–127) IPG removed, n (%): 21 (14.1) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: − Loss to followup: − Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: poor Age: + Baseline OAB status: NR Baseline characteristics: − Length of followup: ++ Measurement methods: − Measurement reliability: − Intervention description: +

Data analysis indicated no differences between males and females in any data recorded

Evidence Table 4 KQ 2 Behavioral Treatment of OAB

Study Description | Study Design, Interventions, and Population | Inclusion/Exclusion Criteria | Symptom Characteristics | Outcomes | Quality Rating
Author: Arruda et al., 2008 Country and setting: Brazil, community Enrollment period: August 2001 to September 2005 Funding: NR Author industry relationship disclosures: None | Design: RCT Intervention: Oxybutynin vs. functional electrostimulation vs. pelvic floor training Groups: G1: Oxybutynin 5 mg b.i.d. G2: Ambulatory stimulation applied vaginally G3: Pelvic floor exercises with a therapist and at home N Screened: 81 N at enrollment: G1: 22 G2: 21 G3: 21 N at follow-up: G1: 22 G2: 21 G3: 21 Age, range: 35–80 Race/ethnicity: NR Women, %: 100 Length of follow up: 12 weeks | Inclusion criteria: • Community-dwelling • Dx of OAB and DO • Capable of completing a bladder diary and performing a pelvic muscle floor contraction • For those with MUI, urge was predominant Exclusion criteria: • Hx of psychiatric or neurologic illness • Persistent UTI • Inability to comply with regular follow-up visits • Current pregnancy • Postvoid residual volume > 100 mL • Contraindications to anticholinergic therapy • Cardiac pacemaker • Type III SUI • Uncontrolled metabolic conditions or indwelling catheterization • Using medications including anticholinergic drugs, calcium antagonists, beta agonists, dopamine agonists, striated muscle relaxants or estrogens • Any uterine prolapse | UUI episodes/week, mean ± SD: G1: 13.8 ± 11.6 G2: 13.5 ± 15.6 G3: 16.4 ± 17.2 Nocturia episodes/week, mean ± SD: G1: 1.7 ± 1.5 G2: 1.9 ± 1.9 G3: 1.4 ± 1.2 Pads/day, mean ± SD: G1: 2.6 ± 2.7 G2: 2.3 ± 2.4 G3: 2.7 ± 1.5 Voids/day, mean ± SD: G1: 7.7 ± 2.6 G2: 8.6 ± 3.4 G3: 6.8 ± 2.2 Residual volume mean mL ± SD: G1: 3.2 ± 6.3 G2: 1.0 ± 2.6 G3: 1.8 ± 3.3 Volume, first desire to void, mean mL ± SD: G1: 117.7 ± 68.9 G2: 102.4 ± 51.1 G3: 86.7 ± 38.9 Maximal cystometric capacity, mean mL ± SD: G1: 410.4 ± 194.1 G2: 350.0 ± 212.9 G3: 424.0 ± 149.0 Involuntary detrusor contraction volume mean mL ± SD: G1: 189.5 ± 114.1 G2: 220.0 ± 127.2 G3: 239.3 ± 163.0 Involuntary detrusor contraction maximal pressure (mm H_2_0 ± SD): G1: 39.4 ± 26.1 G2: 43.7 ± 22.9 G3: 34.2 ± 19.8 | UUI episodes/week, mean ± SD: G1: 7.0 ± 10.6 G2: 7.9 ± 13.7 G3: 7.8 ± 15.3 G1/BL: P = 0.007 G2/BL: P = 0.039 G3/BL: P = 0.035 Urgency resolved, n (%): G1: 14 (63.6) G2: 11 (52.4) G3: 12 (57.1) P = 0.754 Satisfied, n (%): G1: 17 (77.3) G2: 11 (52.4) G3: 16 (76.2) P = 0.142 Nocturia episodes/week, mean ± SD: G1: 0.9 ± 0.8 G2: 1.2 ± 1.3 G3: 1.0 ± 1.1 G1/BL: P = 0.003 G2/BL: P = 0.036 G3/BL: P = 0.086 Pads/day, mean ± SD: G1: 0.9 ± 1.5 G2: 0.9 ± 1.7 G3: 0.8 ± 1.3 G1/BL: P < 0.001 G2/BL: P = 0.004 G3/BL: P < 0.001 Voids/day, mean ± SD: G1: 6.4 ± 1.6 G2: 7.9 ± 2.3 G3: 7.1 ± 2.1 G1/BL: P = 0.014 G2/BL: P = 0.291 G3/BL: P = 0.441 Residual volume, mean mL ± SD: G1: 4.7 ± 9.4 G2: 1.1 ± 2.5 G3: 2.1 ± 3.5 G1/BL: P = 0.425 G2/BL: P = 0.760 G3/BL: P = 0.297 Volume first desire to void, mean mL ± SD: G1: 157.3 ± 63.8 G2: 123.8 ± 59.0 G3: 137.6 ± 76.7 G1/BL: P = 0.019 G2/BL: P = 0.091 G3/BL: P = 0.017 Maximal cystometric capacity mean mL ± SD: G1: 517.3 ± 191.7 G2: 436.6 ± 178.7 G3: 489.0 ± 141.3 G1/BL: P = 0.001 G2/BL: P = 0.017 G3/BL: P = 0.113 Involuntary detrusor contraction volume (mL): G1: 188.6 ± 183.2 G2: 73.3 ± 112.4 G3: 114.3 ± 154.2 G1/BL: P = 0.986 G2/BL: P = 0.001 G3/BL: P = 0.044 Involuntary detrusor contraction maximal pressure, mm H_2_0 ± SD: G1: 19.6 ± 20.9 G2: 22.4 ± 30.1 G3: 17.2 ± 25.5 G1/BL: P < 0.001 G2/BL: P = 0.002 G3/BL: P = 0.027 Normal urodynamic evaluation, n (%): G1: 8 (36.4) G2: 12 (57.1) G3: 11 (52.4) P = 0.358 Persistent improvement at 1 year: G1: 10/17 G2: 4/11 G3: 9/16 Dry mouth, n (%): G1: 16 (72.7) G2: 0 G3: 0 Difficulty voiding, n (%): G1: 2 (9.1) G2: 0 G3: 0 Dizziness, n (%): G1: 1 (4.5) G2: 0 G3: 0 Blurred vision, n (%): G1: 1 (4.5) G2: 0 G3: 0 Constipation, n (%): G1: 1 (4.5) G2: 0 G3: 0 Dry mouth, n (%): G1: 16 (72.7) G2: 0 G3: 0 Difficulty voiding, n (%): G1: 2 (9.1) G2: 0 G3: 0 Dizziness, n (%): G1: 1 (4.5) G2: 0 G3: 0 Blurred vision, n (%): G1: 1 (4.5) G2: 0 G3: 0 Constipation, n (%): G1: 1 (4.5) G2: 0 G3: 0 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: − Method and blinding: − Pt selection criteria: + Loss to followup: + Drop-out rates: − Power calculation: + Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: + Length of followup: + Measurement methods: − Measurement reliability: − Intervention description: +
Author: Bryant et al., 2002 Country and setting: Australia, Specialty treatment centers Enrollment period: NR Funding: NR Author industry relationship disclosures: NR | Design: RCT Intervention: Bladder training plus an educational intervention to reduce caffeine intake to less than 100mg per day vs. bladder training alone Groups: G1: BT + caffeine reduction G2: BT N at enrollment: G1: 48 G2: 47 N at follow-up: G1: 36 G2: 39 Age, yrs ± SD: G1: 56 ± 18 G2: 58 ± 16 Women, %: G1: 94 G2: 87 Weight in kg, mean ± SD: G1: 69 ± 17 G2: 68 ± 20 Race/ethnicity: NR Parity NR | Inclusion criteria: • Adult • Symptoms of urinary urgency, frequency and/or urge incontinence • Routinely ingested ≥ 100mg caffeine/24 hrs Exclusion criteria: • Significant cognitive impairment • Pregnant • Symptoms of UTI | Voids/24 hrs, mean ± SD: G1: 11.4 ± 4.0 G2: 11.2 ± 3.5 Urgency episodes/24 hrs, mean ± SD: G1: 4.8 ± 3.5 G2: 4.6 ± 3.0 Leakages/24 hrs, mean ± SD: G1: 2.8 ± 3.2 G2: 3.1 ± 3.9 Volume/void (mL) mean ± SD: G1: 178 ± 78 G2: 177 ± 101 Caffeine intake/day (mg) mean ± SD: G1: 238.7 ± 121 G2: 272 ± 184 Duration of urinary symptoms (yrs), mean ± SD: G1: 13.7 ± 14.9 G2: 10.7 ± 15.5 | Leakages/24 hrs, mean ± SD: G1: 1.2 ± 1.9 G2: 1.4 ± 1.7 Mean reduction in leakages/24 hrs, %: G1: 55 G2: 26 P = 0.219 Voids/24 hrs, mean ± SD: G1: 6.8 ± 2.0 G2: 7.9 ± 2.6 Urgency episodes per 24 h, mean ± SD: G1: 1.6 ± 1.9 G2: 3.2 ± 2.8 Mean reduction in voids/24 hrs,%: G1: 35 G2: 23 P = 0.037 Mean reduction in urgency episodes/24 hrs, %: G1: 61 G2: 12 P = 0.002 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: + Masking: − Pt selection criteria: + Loss to follow up: − Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of follow up: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Burgio et al., 1998 Country and setting: US, academic health center outpatient geriatric medicine clinic Enrollment period: July 1989 to August 1995 Funding: National Institutes on Aging Author industry relationship disclosures: NR | Design: RCT, placebo controlled Computer-generated random numbers using a block size of 6, w/prior stratification by type and severity of incontinence Intervention: Biofeedback-assisted behavioral vs. drug treatment (oxybutynin chloride; possible range of doses 2.5 mg/d-5.0 mg t.i.d.) vs. placebo All patients had 4 visits over an 8-week period. Patients in G1 had biofeedback added to behavioral training in absence of 50% improvement by session 3. Groups: G1: Behavioral ± biofeedback G2: Pharmacologic G3: Placebo N at enrollment: 468 screened 271 not eligible 197 randomized G1: 65 G2: 67 G3: 65 N at follow-up: G1: 61 G2: 55 G3: 53 Women, %: 100 Age, yrs ± SD: G1: 67.3 ± 7.6 G2: 68.2 ± 7.5 G3: 67.6 ± 7.6 Race/ethnicity: NR Parity mean ± SD: G1: 2.8 ± 2.0 G2: 2.1 ± 1.4 G3: 2.7 ± 1.8 P < 0.05 | Inclusion criteria: • Community-dwelling women at least age 55 • Ambulatory • At least 2 urge accidents per week by baseline bladder diary • Urge incontinence as predominant pattern • Urodynamic evidence of bladder dysfunction Exclusion criteria: • Continual leakage • Postvoid residual urine volume >200mL • Uterine prolapse past the entroitus • Narrow-angle glaucoma • Unstable angina • Decompensated congestive heart failure • Hx of malignant arrhythmias • MMSE <20 (Dementia) | Duration of symptoms, mean yrs ± SD: G1: 9.4 ± 10.8 G2: 9.8 ± 11.9 G3: 12.7 ± 15.9 Restricted activity, (%): G1: 30.8 G2: 32.8 G3: 38.5 Urge UUI only, %: G1: 49.2 G2: 49.3 G3: 47.7 Accidents per week, mean ± SD: G1: 15.8 ± 14.5 G2: 15.9 ± 14.1 G3: 15.4 ± 13.4 P = .98 Severity classification, %: Mild (<5 accidents/wk) G1: 18.5 G2: 17.9 G3: 18.5 Moderate (5–10 accidents/wk) G1: 29.2 G2: 29.9 G3: 27.7 Severe (>10 accidents/wk) G1: 52.3 G2: 52.2 G3: 53.8 Previous treatment with surgery, %: G1: 20.0 G2: 26.9 G3: 29.2 Previous treatment with medication, %: G1: 27.7 G2: 35.8 G3: 30.8 Using estrogen, %: G1: 32.3 G2: 38.8 G3: 35.4 Using diuretics, %: G1: 20.0 G2: 14.9 G3: 12.3 | Accidents per week, mean ± SD: G1: 2.8 ± 4.7 G2: 5.7 ± 9.8 G3: 8.2 ± 11.6 P = 0.005 Percent reduction, mean ± SD: G1: 80.7 ± 24.8 G2: 68.5 ± 37.2 G3: 39.4 ± 80.0 P < 0.001 Percent reduction, range: G1: −0.9 – 100 G2: −85.7 – 100 G3: −400.0 − 100 Patient perceptions of progress in treatment Much better G1: 74.1 G2: 50.9 G3: 226.9 Better G1: 25.9 G2: 30.9 G3: 38.5 About the same G1: 0.0 G2: 16.4 G3: 28.8 Worse G1: 0.0 G2: 1.8 G3: 5.8 Estimate of % improvement, mean ± SD: G1: 81.6 ± 18.6 G2: 66.4 ± 35.4 G3: 45.1 ± 36.6 Having fewer accidents, %: G1: 100.0 G2: 87.3 G3: 67.3 Accidents are smaller, %: G1: 87.3 G2: 78.8 G3: 54.0 Able to wear less protection, %: G1: 76.0 G2: 56.0 G3: 334.1 Comfortable enough with treatment to continue indefinitely, %: G1: 96.5 G2: 54.7 G3: 43.1 Patient satisfaction with progress, %: Completely satisfied G1: 77.6 G2: 54.7 G3: 43.1 Somewhat satisfied G1: 22.4 G2: 40.0 G3: 34.0 Not at all satisfied G1: 0.0 G2: 10.9 G3: 38.0 Wish to receive another form of treatment, %: G1: 14.0 G2: 75.5 G3: 75.5 P < 0.001 for all comparisons Adverse effects, %, p compared to placebo G3: Dry mouth, %: G1: 34.9 G2: 96.9 G3: 54.8 P < 0.001 Inability to void, %: G1: 6.3 G2: 21.5 G3: 3.2 P = 0.002 Constipation, %: G1: 22.2 G2: 38.5 G3: 37.1 P = 0.10 Blurred vision, %: G1: 9.5 G2: 15.4 G3: 9.7 P = 0.50 Confusion, %: G1: 6.3 G2: 7.7 G3: 11.3 P = 0.59 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to follow up: + Drop-out rates: + Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of follow up: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Burgio et al.. 2000 [See Burgio et al., 1998] Enrollment period: Two weeks after completion of Burgio et al. 1998 Funding: National Institute on Aging, grants AG 08010 and K04 00431 Author industry relationship disclosures: NR | Design: Modified crossover of RCT Intervention: Participants whose treatment was not completely successful were given the opportunity to switch or use combined treatment; further reductions in incontinence were measured. Groups: [underlined: Treatment Changes:] G1: Previous oxybutynin to behavioral modification alone G2: Previous behavior alone to 2.5 mg oxybutynin t.i.d. + behavioral therapy G3: Previous oxybutynin alone to 2.5 mg oxybutynin t.i.d. + behavioral therapy G4: Placebo to behavioral G5: Placebo to oxybutynin N at enrollment G1: 19 G2: 8 G3: 27 G4: 34 G5: 10 N at follow-up: G1: 18 G2: 8 G3: 26 G4: NR G5: NR | Inclusion criteria: • Community-dwelling women at least age 55 • Ambulatory • At least 2 urge accidents per week by baseline bladder diary • Urge incontinence as predominant pattern • Urodynamic evidence of bladder dysfunction • Not completely dry or satisfied with previous, 8-wk treatment Exclusion criteria: • Continual leakage • Postvoid residual urine volume >200mL • Uterine prolapse past the introitus • Narrow-angle glaucoma • Unstable angina • Decompensated congestive heart failure • Hx of malignant arrhythmias • MMSE <20 (Dementia) | % Reduction of incontinence after previous study (at baseline), mean: G1: 59.1 G2: 57.5 G3: 72.7 G4: 22.9 G5: 44.8 | Final % Reduction of incontinence mean, p: G1: 77.1, 0.109 G2: 88.5, 0.034 G3: 84.3, 0.001 G4: 63.9, .002 G5: 76.5, .012 Note: 29.2 of G3 declined to continue with drug therapy once they received behavioral modification. Numbers were too low to compare across groups. | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to follow up: + Drop-out rates: + Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of follow up: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Burgio et al., 2001 [See Burgio et al,. 1998] Country and setting: US, University based Enrollment period: [See Burgio et al., 1998] Funding: NIH Author industry relationship disclosures: NR | Design: RCT Intervention: Psychological distress associated with pharmacologic treatment vs. behavioral vs. placebo Groups: G1: Behavioral training with biofeedback, 4 visits G2: Oxybutynin 2.5 mg po t.i.d., up to a max of 5 mg t.i.d. G3: Placebo N at enrollment: 197 women N treated: 169 N at follow-up: 155 (completed both pre and post-treatment psychological assessment) Age yrs, mean ± SD: 67.5 ± 7.2 Women, %: 100 Race/ethnicity, %: White: 97 African American: 3 | Inclusion criteria: • ≥ 55 yrs old • ambulatory • UUI ≥2x/wk (2 wk bladder diary), persisting × 3 mos • Predominant UUI • Urodynamic evidence of bladder dysfunction (DI or maximal capacity ≤350 mL) Exclusion criteria: • contraindication to oxybutynin or behavioral treatment • Continual leakage • Post void residual > 200 mL • Uterine prolapse beyond the introitus • Decompensated CHF • Hx of malignant arrhythmias • Impaired mental status (MMSE <20) | SCL-90-R scores mean (SD): Somatization G1: 56.0 (10.6) G2: 51.4 (10.8) G3: 52.4 (11.1) Obsessive-Compulsive: G1: 56.5 (10.7) G2: 56.6 (11.4) G3: 57.7 (10.0) Interpersonal Sensitivity G1: 53.8 (11.0) G2: 51.4 (11.9) G3: 50.4 (12.0) Depression G1: 54.7 (10.0) G2: 52.5 (9.7) G3: 51.0 (11.9) Anxiety G1: 48.7 (13.9) G2: 46.8 (12.0) G3: 47.2 (12.8) Hostility G1: 49.3 (10.7) G2: 45.9 (10.1) G3: 48.3 (10.4) Phobia G1: 47.5 (10.2) G2: 46.7 (10.3) G3: 45.7 (8.5) Paranoid Ideation G1: 48.6 (12.4) G2: 49.3 (11.1) G3: 46.1 (12.8) Psychoticism G1: 54.1 (10.7) G2: 52.1 (10.3) G3: 50.5 (11.2) Global Severity G1: 54.2 (11.1) G2: 52.5 (10.3) G3: 52.4 (11.2) 155 participants were compared to the 42 who did not complete intervention and psychological assessment, higher scores (greater distress) on 6 of 10 SCL-90-R scales (somatization, obsessive/compulsive, depression, hostility, paranoid ideation, global severity index), all p values <0.05 Normal range, score 0–63 >75% in normal range (including dropouts) on 9 of 10 scales Highest impairment rate: 33% scored abnormal for obsessive-compulsive | Reduced incontinence episodes: G1: 83.3% G2: 74.4% G3: 41.4% P < 0.001 SCL-90-R scores (SD): Somatization G1: 51.8 (11.4) G2: 51.2 (9.8) G3: 49.8 (13.0) Obsessive-Compulsive: G1: 53.8 (13.9) G2: 53.9 (10.9) G3: 55.4 (11.0) Interpersonal sensitivity G1: 49.5 (12.0) G2: 48.9 (11.2) G3: 49.2 (11.3) Depression G1:51.5 (11.5) G2: 50.6 (10.7) G3: 51.4 (11.2) Anxiety G1: 46.1 (14.6) G2: 44.5 (12.3) G3: 45.8 (12.9) Hostility G1: 44.9 (10.8) G2: 44.6 (10.5) G3: 47.3 (11.2) Phobia G1: 47.1 (11.2) G2: 45.0 (8.3) G3: 45.1 (8.5) Paranoid ideation G1: 45.8 (10.9) G2: 47.2 (11.6) G3: 47.2 (12.0) Psychoticism G1: 49.2 (11.7) G2: 50.4 (9.7) G3: 49.6 (10.3) Global Severity G1: 50.8 (12.8) G2: 50.4 (10.0) G3: 51.4 (10.9) Correlations between reduction of incontinence and changes in psychological symptoms: Somatization G1: 0.28* G2: −0.09 G3: 0.17 Obsessive-Compulsive G1: 0.01 G2: −0.14 G3: 0.02 Interpersonal Sensitivity G1: −0.09 G2: 0.04 G3: 0.13 Depression G1: −0.04 G2: 0.03 G3: 0.07 Anxiety G1: −0.10 G2: −0.01 G3: 0.34* Hostility G1: −0.10 G2: 0.09 G3: 0.11 Phobic anxiety G1: −0.21 G2: −0.17 G3: 0.02 Paranoid Ideation G1: 0.14 G2: −0.04 G3: −0.06 Psychoticism G1: −0.01 G2: −0.01 G3: 0.13 Global Severity Index G1: 0.01 G2: 0.06 G3: 0.45*** *P < 0.05 ***P = 0.001 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to follow up: + Drop-out rates: + Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of follow up: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Burgio et al., 2002 Country and setting: US, Academic medical center Enrollment period: April 1995 to March 2001 Funding: NIH Author industry relationship disclosures: NR | Design: RCT Intervention: Behavioral training with or without biofeedback for 8 wks compared to self-training, followed by 2 wks of post-treatment bladder diaries and a patient satisfaction questionnaire Groups: G1: Behavioral training with biofeedback G2: Behavioral training with verbal feedback G3: Self-administered behavioral training N at enrollment: Evaluated: 474 Excluded: 252 Randomized: 222 G1: 73 G2: 74 G3: 75 N at follow-up: G1: 62 G2: 65 G3: 68 Women, %: 100 Age, mean ± SD: G1: 64.8 ± 7.1 G2: 65.8 ± 7.6 G3: 65.8 ± 8.5 Race/ethnicity, n (%): Black: G1: 11 (15.1) G2: 13 (17.6) G3: 11 (14.7) Parity, mean ± SD: G1: 2.5 ± 1.7 G2: 3.0 ± 2.0 G3: 2.7 ± 2.0 Using estrogen, n (%): G1: 52 (72.2) G2: 51 (68.9) G3: 44 (59.5) | Inclusion criteria:* Women Age ≥ 55 Community-dwelling Ambulatory Predominant urge incontinence ≥ 2x/wk for at least 3 mos Urodynamic evidence of bladder dysfunction Exclusion criteria: • Continual leakage • PVR ≥ 150mL • Severe uterine prolapse past uterine introitus • Decompensated congestive heart failure • MMSE score <24 | Incontinence episodes/week, mean ± SD: G1: 15.1 ± 13.5 G2: 17.3 ± 16.3 G3: 15.4 ± 14.2 P = 0.62 < 5 incontinence episodes/wk, n (%): G1: 14 (19.2) G2: 14 (18.9) G3: 16 (21.3) 5–10 incontinence episodes/wk, n (%): G1: 20 (27.4) G2: 21 (28.4) G3: 21 (28.0) > 10 incontinence episodes/wk, n (%): G1: 39 (53.4) G2: 39 (52.7) G3: 38 (50.7) P > 0.99 UUI, n (%): G1: 50 (68.5) G2: 50 (67.6) G3: 50 (66.7) MUI, n (%): G1: 23 (31.5) G2: 24 (32.4) G3: 25 (33.3) P = 0.97 Duration of symptoms (yrs), mean ± SD: G1: 7.1 ± 7.8 G2: 6.6 ± 7.7 G3: 6.6 ± 8.7 Previous treatment with medication, n (%): G1: 16 (21.9) G2: 18 (24.3) G3: 21 (28.0) Previous treatment with surgery, n (%): G1: 16 (21.9) G2: 13 (17.6) G3: 12 (16.0) Bladder capacity (mL), mean ± SD: G1: 282 ± 117 G2: 238 ± 100 G3: 266 ± 105 P = 0.04 | Incontinence episodes/week, mean ± SD: G1: 6.1 ± 10.3 G2: 6.0 ± 10.7 G3: 6.7 ± 11.4 P = 0.78 Incontinence episodes/week, % change, mean ± SD: G1: −63.1 ± 42.7 G2: −69.4 ± 32.7 G3: −58.6 ± 38.8 P = 0.23 Incontinence episodes/week, % change, median (IQR): G1: −75.0 (−100, 120.0) G2: −82.8 (−100, 0) G3: −70.4 (−100, 29.4) Fewer incontinence episodes, n (%): G1: 51 (96.2) G2: 57 (100) G3: 58 (92.1) P = 0.09 Smaller accidents, n (%): G1: 42 (79.2) G2: 49 (89.1) G3: 42 (67.7) G2/G3: P = 0.006 G1/G2/G3: P = 0.02 Able to wear less protection, n (%): G1: 33 (71.7) G2: 40 (83.3) G3: 34 (70.8) P = .29 Much better progress, n (%): G1: 33 (62.3) G2: 36 (63.2) G3: 20 (30.8) Better progress, n (%): G1: 18 (34.0) G2: 20 (35.1) G3: 36 (55.4) No Progress, n (%): G1: 2 (3.8) G2: 1 (1.8) G3: 8 (12.3) Worse, n (%): G1: 0 G2: 0 G3: 1 (1.5) G2/G3: P < 0.001 G1/G3: P < 0.001 G1/G2/G3: P < 0.001 Comfortable enough to continue treatment indefinitely, n (%): G1: 49 (98.0) G2: 54 (100) G3: 54 (88.5) G2/G3: P = 0.01 G1/G2/G3: P = 0.009 Completely satisfied with progress, n (%): G1: 39 (75.0) G2: 47 (85.5) G3: 34 (55.7) Somewhat satisfied with progress, n (%): G1: 12 (23.1) G2: 8 (14.5) G3: 24 (39.3) Not at all satisfied with progress, n (%): G1: 1 (1.9) G2: 0 G3: 3 (4.9) G2/G3: P < 0.001 G1/G3: P = 0.03 G1/G2/G3: P < 0.001 Incontinence restricts activities-not at all, n (%): Not at all: G1: 36 (69.2) G2: 43 (78.2) G3: 31 (50.8) Incontinence restricts activities- some or all, n (%): G1: 16 (30.8) G2: 12 (21.8) G3: 30 (49.2) G2/G3: P = 0.002 G1/G3: P = 0.047 G1/G2/G3: P = 0.007 Not at all disturbed about incontinence, n (%) G1: 26 (49.1) G2: 32 (59.3) G3: 23 (39.0) Somewhat disturbed about incontinence, n (%): G1: 26 (49.1) G2: 22 (40.7) G3: 32 (54.2) Extremely disturbed about incontinence, n (%): G1: 1 (1.9) G2: 0 G3: 4 (6.8) P = 0.18 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: + Masking: − Pt selection criteria: + Loss to follow up: + Drop-out rates: + Power calculation: + Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of follow up: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Burgio et al., 2008 Country and setting: US, Academic medical centers Enrollment period: July 2004 to January 2006 Funding: NIH Pfizer Author industry relationship disclosures: 20 of 29 Allergan (3) Alza (1) Astellas Pharma (7) Bionovo (1) Bristol-Meyers Squibb (1) Dynogen (1) Elan (1) Ethicon (2) GSK (4) Johnson & Johnson (3) Lilly (7) Medtronic (1) Merck (1) Novartis (6) Ortho-McNeil (3) Pfizer (>10) Procter & Gamble (3) Q-Med (1) Renessa (1) Sanofi (1) Solace (1) Watson (1) | Design: RCT Intervention: Pharmacologic vs. pharmacologic plus behavioral interventions for 10 wks (Stage 1), followed by no drug therapy (Stage 2) with assessments at 10 wks and 8 mos* Groups: G1: Tolterodine tartrate (ER capsules), 4 mg/d plus behavioral training: pelvic floor muscle control and exercises, behavioral strategies to diminish urgency, suppress bladder contractions and prevent both stress and urge incontinence; delayed voiding; fluid management; handout with hints G2: Tolterodine tartrate (ER capsules), 4 mg/d N at enrollment: 4043 screened 2612 not eligible 870 declined 561 consented 254 excluded 307 randomized G1: 153 G2: 154 N at follow-up: G1: 153 Completed treatment: 107 Outcome known at 8 mos: 119 G2: 154 Completed treatment: 101 Outcome known at 8 mos: 118 Age, mean ± SD: G1: 55.8 ± 14.2 G2: 58.0 ± 13.5 Women, %: 100 Race/ethnicity, n (%): Hispanic: G1: 13 (9) G2: 17 (11) NH White: G1: 105 (69) G2: 85 (56) NH Black: G1: 22 (14) G2: 35 (23) Other: G1: 13 (9) G2: 15 (10) BMI, kg/m^2^ ± SD: G1: 33.2 ± 9.5 G2: 32.3 ± 7.6 | Inclusion criteria: • Women • Community-dwelling • UUI only, or urge-predominant • ≥ 7 episodes of incontinence in a 7-day bladder diary • Persistent incontinence for at least 3 mos • No current use of antimuscarinics or other medications that could affect UI • No evidence of neurogenic etiology Exclusion criteria: • Age < 21 • Pregnant, planning a pregnancy in next 8 mos, or not using birth control • < 6 mos postpartum or termination after 20 wks gestation • Unable to contract pelvic floor muscles during evaluation • Behavioral therapy of > 2 mos in past 2 yrs • Continual leakage or always damp • Hypersensitive to study drug • Systemic disease that affects bladder function • Currently using catheter to empty bladder • Postvoid residual volume > 150mL • Treatment for prolapse with pessary < 3 mos • Incontinence, vaginal, bladder or prolapse surgery in the past 6 mos • Urethral diverticulum • Previous augmentation cystoplasty or artificial sphincter • Neuromodulation for pelvic indications • Using anticholinergic agents, cholinergic agonists, tricyclic antidepressants, or duloxetine in ≤ 4 wks • Using diuretics with dosage change past 3 mos • Uncontrolled medical problem • History of bladder or pelvic cancer or pelvic radiation therapy • Glaucoma • Gastric retention • Non-ambulatory • Participation in other intervention trial that might influence outcome | UUI, 7–13 episodes/week, n (%): G1: 2 (1.3) G2: 2 (1.3) UUI, ≥ 14 episodes/week, n (%): G1: 2 (1.3) G2: 4 (2.6) MUI, 7–13 episodes/week, n (%): G1: 46 (29.9) G2: 46 (30.1) MUI, ≥ 14 episodes/week, n (%): G1: 104 (67.5) G2: 101 (66.0) Adjusted incontinence episodes/week, mean: G1: 23.1 G2: 23.2 Previous non-surgical treatment for incontinence, n (%): G1: 19 (12) G2: 22 (14) | Success, n (%): G1: 43 (28) G2: 41 (27) Failure, n (%): G1: 75 (49) G2: 78 (51) Success rate, 8 months, lifetable analysis, % (95% CI): G1: 41 (32, 50) G2: 41 (33, 50) G1/G2: 0 (−12, 12) Success rate, 8 months, complete cases, % (95% CI): G1: 36 (27, 45) G2: 34 (25, 43) G1/G2: 2 (−10, 14) Success rate, 8 mos, assuming missings were failures, % (95% CI): G1: 28 (21, 35) G2: 27 (20, 34) G1/G2: 1 (−9, 11) Adjusted incontinence episodes/week, after Stage 1, mean: G1: 2.7 G2: 4.7 Adjusted incontinence episodes/week, after Stage 1, mean change: G1: −20.4 G2: −18.5 G1/G2: −1.9 (−5.9, 2.0) Achieved 70% reduction in incontinence episodes, per bladder diary, 10 weeks (%): G1: 69 G2: 58 G1/G2: 11 (−0.3, 22.1) Totally dry, per bladder diary, 10 weeks (%): G1: 21 G2: 17 Voids/day, mean change: G1: 0.5 G2: −0.4 G1/G2: 0.9 (0.3, 1.5) Symptom Distress Scores: G1/G2: P < 0.0001 Symptom Bother Scores (OAB-q), Stage 1, mean change: G1: −36.7 G2: −30.4 G1/G2: P < 0.0001 Symptom Bother Scores (OAB-q), Stage 2, mean change: G1: −30.9 G2: −20.4 G1/G2: P < 0.0001 Patient completely satisfied, Stage 1, %: G1: 53 G2: 40 G1/G2: 13 (1, 25) Patient completely satisfied, 8 months, %: G1: 33 G2: 20 G1/G2: 13 (2, 24) Patient better or much better, Stage 1, %: G1: 90 G2: 77 G1/G2: 13 (4, 22) Patient better or much better, 8 months, %: G1: 69 G2: 43 G1/G2: 26 (14, 38) Persistence in perceived improvement, 8 mos, women with improvement at Stage 1: G1: 72 G2: 54 G1/G2: 17 (4, 30) Harms: G1: 3 participants 1: blurred vision, syncope, night sweats, stomach cramping and weakness 2: 2 episodes of small-bowel obstruction and an allergic reaction (pruritus and rash) 3: tachycardia during stage 2 G2: 3 participants 1: small bowel obstruction 2: peripheral edema 3: renal cell carcinoma diagnosis during stage 2 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: − Pt selection criteria: + Loss to followup: − Drop-out rates: ++ Power calculation: + Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Colombo et al., 1995 Country and setting: Italy; Setting Enrollment period: May 1990 to March 1993 Funding: NR Author industry relationship disclosures: NR | Design: RCT Intervention: Oxybutynin vs. Bladder training for 6 weeks Groups: G1: Oxybutynin, 3 daily doses of 5 mg each for 6 weeks (dose reduced to half if substantial AEs) G2: Bladder training N at enrollment: G1: 42 G2: 39 N at 6 wk follow-up: G1: 38 G2: 37 N at 6 mo follow-up: G1: 28 G2: 27 Age, yrs ± SD: G1: 48 (31 – 65) G2: 49 (24 – 65) Race/ethnicity, mean ± SD: Black: NR Women, N (%): G1: 42 (100) G2: 39 (100) Postmenopausal n (%): G1: 16 (38) G2: 20 (51) | Inclusion criteria: • Socially embarrassing (severe) urinary urge incontinence • On cystometry: detrusor instability, or low-compliance bladder (LCB), or sensory bladder Exclusion criteria: • Stable bladder at cystometry • Neurologic disease • Detrusor hyperreflexia • Age greater than 65 yr • Coexisting genuine SUI • Genital prolapse • Postvoid residual volume >50mL • Previous gynecologic or urogynecologic surgery • Prior use of any drug to treat UUI • Urethral diverticula • Fistulas • Urinary tract neoplasia • Cystitis • Bladder stones • Previous pelvic radiotherapy | Detrusor instability, n (%): G1: 14 (37) G2: 13 (35) Low compliance bladder, n (%): G1: 9 (24) G2: 8 (22) Sensory bladder, n (%): G1: 15 (39) G2: 16 (43) Daily UUI episodes, range 9 – 17 Diurnal frequency, n (%): G1: 32 (84) G2: 29 (78) Nocturia, n (%): G1: 11 (29) G2: 18 (49) Volume at first desire (mL): G1: 120 ± 59 G2: 134 ± 61 Volume at very strong desire (mL): G1: 317 ± 92 G2: 332 ± 87 | Clinically cured overall, n (%): G1: 28 (74) G2: 27 (73) Cured among DI, (%): G1: 13 (93) G2: 8 (62) P = 0.07 Cured among LCB: G1: 6 (67) G2: 6 (75) P = 0.56 Cured among sensory bladder: G1: 9 (60) G2: 13 (81) P = 0.18 Cured among 18 G1 patients requiring dosage halving: 12 (67%) Diurnal frequency resolved, n (%): G1: 18 (56) G2: 20 (69) Nocturia resolved n (%): G1: 3 (27) G2: 11 (61) Volume at first desire (mL), mean ± SD: G1: 179 ± 32 P = .0009 G2: 178 ± 49 P = .001 Volume at very strong desire (mL) mean ± SD: G1: 408 ± 76 P = .00001 G2: 403 ± 69 P = .0002 Patients still cured at 6 mos, n: G1: 16 G2: 26 Patients still cured at 6 mos among DI, n: G1: 8 G2: 8 Patients still cured at 6 mos among LCB, n: G1: 4 G2: 6 Patients still cured at 6 mos among sensory bladder, n: G1: 4 G2: 12 Treatment discontinued in 6 cases: G1: 4 (3 cases of severe dry mouth, 1 case of previously unknown glaucoma) G2: 2 (treatment was time consuming) Other adverse effects G1: 18 (47%) with AE requiring halving of dosage: -dry mouth (n=15) -constipation (n=6) -nausea (n=5) -dizziness (n=2) - decrease in visual acuity (n=1) - tachycardia (n=1) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: + Masking: − Pt selection criteria: + Loss to follow up: ++ Drop-out rates: + Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of follow up: − Measurement methods: + Measurement reliability: − Intervention description: +
Author: Diokno et al., 1995 Country and setting: US; private clinic Enrollment period: January 1992 to December 1992 Funding: NR Author industry relationship disclosures: NR | Design: Cohorts with comparison; (Series of patients self selected into two groups) Intervention: Bladder training vs. anticholinergic or antispasmodic Groups: G1: Bladder training G2: oxybutynin 2.5–5.0 mg b.i.d. or t.i.d. N at enrollment: G1: 39 G2: 33 N at follow-up: G1: 26 G2: 28 Age, mean yrs (range): 64 (20–93) Race/ethnicity: NR Women, N (%): 72 (100) Parity: NR | Inclusion criteria: • Incontinent by AHCPR guidelines* • Incontinence persisted after treatment for transient incontinence Exclusion criteria: • Post-void residual of more than 150 mL | UUI, n (%): G1: 27 (49) G2: 28 (51) MUI with predominant urge, n (%): G1: 12 (71) G2: 5 (29) | Continent, n (%): G1: 1 (4) G2: 1 (4) Improved, n (%): G1: 22 (85) G2: 19 (68) No Change, n (%): G1: 3 (11) G2: 8 (28) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: − Loss to follow up: − Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: poor Age: −, NR Baseline OAB status: NR Baseline characteristics: − Length of follow up: ++ Measurement methods: − Measurement reliability: − Intervention description: +
Author: Dorey et al., 2006 Country and setting: UK, Urogynecology clinic Enrollment period: January 2002 to July 2004 Funding: NR Author industry relationship disclosures: NR | Design: Retrospective review of cases Intervention: Physiotherapeutic treatment, avg. 3 sessions, including: PFME Urge suppression techniques Fluid advice Dietary advice Groups: NA N at enrollment: 87 N at follow-up: 66 13 (15%) excluded for SUI 7 (8%) LTFU 1 (1%) self-catherized Women, n (%): 87 (100) Age, mean yrs (range): 56 (29–79) Race/ethnicity: NR BMI >30, %: 20 Parous, n (%): 79 (91) Prior pelvic surgery, n (%): 60 (69) Prior hysterectomy, n (%): 30 (35) | Inclusion criteria: • Treated for UUI from Jan 2002 to Jul 2004 Exclusion criteria: • Severe stress urinary incontinence • Self-catherization | Daily leakage, n (%): 44 (67) Strong pelvic floor muscles, %: 75 | Significant improvement in UUI, n (%): 55 (83) Daily leakage, n (%): 8 (12) 100 % improvement, n (%): 8 (12) ≥80% improvement, n (%): 24 (37) 50–75% improvement, n (%): 31(48) Slight improvement, n (%): 6 (9) No improvement, n (%): 4 (6) No UUI at discharge, n (%): 5 (8) Mild UUI at discharge, n (%): 46 (69) Moderate UUI at discharge, n (%): 12 (18) Severe UUI at discharge, n (%): 4 (6) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: − Loss to follow up: NR Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of follow up: NA Measurement methods: − Measurement reliability: − Intervention description: +
Author: Dowd et. al., 2003 Country and setting: US, Community Enrollment period: NR Funding: Kidney Foundation of Ohio Author industry relationship disclosures: NR | Design: Cohorts with comparison, patients alternately assigned to 3 groups Intervention: G1: Pamphlet plus CS plus coaching G2: Pamphlet plus cognitive strategies (CS) via audiotape daily for 4 wks then 1x wk until 12 wks G3: Pamphlet on bladder health, etc. Groups: G1: Bladder health information + CS + coaching G2: Bladder health information + CS G3: Bladder health information N at enrollment: Total: 58 N at follow-up: G1: 18 G2: 18 G3: 14 Women, n (%): G1: 17 (94) G2: 18 (100) G3: 13 (93) P = 0.54 Age, mean: G1: 68.7 G2: 59.6 G3: 57.1 P = 0.03 Race/ethnicity: NR | Inclusion criteria: • Adults • Living independently • No major hearing problem, • Able to read and write English, • CUBS for 6 mos or more • MMSE score >20 • Negative urine screen Exclusion criteria: • See inclusion criteria | UUI, %: G1: 26.7 G2: 31.6 G3: 33.3 SUI or MUI, %: G1: 73.3 G2: 68.4 G3: 66.7 | Comfort (UFIQC): Persons in G1 and G3 saw modest gains over time; G2 did not. Significant group-by-type of UI interaction: G1 and G3 with urge had more improvement than participants with stress or other UI (F=3.61; P = .037) Bladder Function (BFQ): Significant change for all groups (F=13.31; P = 0.0001); No significant interactions by type of incontinence by significant main effect for urge | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to follow up: − Drop-out rates: ++ Power calculation: + Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: NR Baseline characteristics: − Length of follow up: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Fantl et al., 1981 Country and setting: US, University Enrollment period: N/A Funding: NR Author industry relationship disclosures: NR | Design: Retrospective chart review Intervention: Bladder retraining drill (BRD) and anticholinergics when BRD not satisfactory Groups: G1: Detrusor muscle contraction approximately 5 seconds after a cough G2: Detrusor muscle contracts spontaneously without prior provocation G3: Both cough contraction and spontaneous contraction N at enrollment: G1: 39 G2: 4 G3: 49 N at follow-up: NA Women, %: 100 Age, mean ± SD: 42.7 ± 10:3 Race/ethnicity: NR Parity, mean: 3.5 | Inclusion criteria: • Cystometric tracings showed a rise of 15 cm water or more in intravesical pressure when recorded independently and calculated by subtraction from intra-abdominal transrectal pressures Exclusion criteria: • Neuropathic conditions • UTI | Urgency and frequency, n (%): 72 (78.2) Urinary incontinence, n (%): 65 (70.6) Sensation of incomplete voiding, n (%) 59 (64.1) Nocturia, n (%): 66 (71.7) Dysuria, n (%): 3 (3.2) MUI, n (%): 6 (6.5) Enuresis in childhood, n (%): 5 (5.4) Previously operated on for similar urologic symptoms, n (%): 34 (36.9) | Cured, n (%): G1: 32 (82.1) G2: 1 (25) G3: 41 (83.7) Cured by BRD alone, n (%): 44 (78.6) Cured by BRD + anticholinergics, n (%):* 30 (83.5) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to follow up: NR Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of follow up: NA Measurement methods: + Measurement reliability: − Intervention description: −
Author: Frewen, 1982 Country and setting: UK; Outpatient clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR | Design: Case series Intervention: Bladder training Groups: NA N at enrollment: 90 N at follow-up: 90 Age, range: 15–75 Race/ethnicity: NR Women, N (%): 90 (100) Parity mean ± SD: NR | Inclusion criteria: • Consecutive patients presenting with frequency, urgency and/or urge incontinence Exclusion criteria: • NR | Urgency incontinence, n (%): 63 (70) Detrusor Instability, n (%): NR (63) Frequency, n: 10 Diurnal-nocturnal enuresis, n: 20 Duration of symptoms, yrs (range): stable: 4–5 unstable: 12 Results of cystometry in 82 patients, n: Unstable: 40 | Cure, n (%):* 78 (86.6) Free from incontinence (but residual urgency), n (%): 12 (13.4) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: − Loss to follow up: ++ Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: + Length of follow up: NA Measurement methods: + Measurement reliability: + Intervention description: +
Author: Ghei et al., 2006 Country and setting: UK, Primary care Enrollment period: NR Duration 16 weeks Funding: NR Author industry relationship disclosures: NR | Design: Observational cohort Intervention: Bladder retraining vs. Bladder retraining + antimuscarinic (oxybutynin IR/ ER, tolterodine IR/ER, or imipramine combined with either oxybutynin or tolterodine as combination therapy) Groups: G1: Bladder retraining alone G2: Antimuscarinic therapy+ bladder retraining N at enrollment: G1: 52 G2: 656 N at follow-up: G1: 46 G2: 501 Women, n (%): G1: 45 (86) G2: 618 (94) Age, mean ± SD: G1: 52 ± 14 G2: 54 ± 23 Race/ethnicity: NR | Inclusion criteria: • Frequency • Urgency with or without UUI Exclusion criteria: • SUI • Symptoms of BOO | Incontinence episodes/day, mean ± SD: G1: 0.47 ± 1.2 G2: 1.12 ± 1.7 P < 0.001 Voids/day, mean ± SD: G1: 14 ± 6 G2: 11 ± 6 P = 0.001 | Incontinence episodes/day, mean change difference (95% CI): G2/G1: −0.60 (−0.93, −0.27) P = 0.024 Voids/day, mean change difference (95% CI): G2/G1: 2.35 (1.4, 3.3) P < 0.001 Nocturia episodes/day, mean change difference (95% CI): G2/G1: 0.57 (0.15, 0.99) Attendance visits, n (%) Failed follow-up: G1: 6 (12) G2: 155 (23) 1 follow-up visit: G1: 10 (19) G2: 15 (2) 2 follow-up visits: G1: 18 (35) G2: 86 (13) 3 follow-up visits: G1: 9 (17) G2: 225 (35) 4 follow-up visits: G1: 9 (17) G2: 175 (27) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to follow up: − Drop-out rates: NR Power calculation: − Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: + Length of follow up: + Measurement methods: + Measurement reliability: − Intervention description: +
Author: Goode et al., 2002 Country and setting: US; academic health center outpatient geriatric medicine clinic Enrollment period: July 1989 to August 1995 Funding: National Institutes on Aging Author industry relationship disclosures: NR | Design: RCT, placebo controlled Computer-generated random numbers using a block size of 6, w/prior stratification by type and severity of incontinence Intervention: Biofeedback-assisted behavioral vs. drug treatment (oxybutynin chloride; possible range of doses 2.5 mg/d-5.0 mg t.i.d.) vs. placebo All patients had 4 visits over an 8-week period. Patients in G1 had biofeedback added to behavioral training in absence of 50% improvement by session 3. Groups: G1: Behavioral ± biofeedback G2: Pharmacologic G3: Placebo N at enrollment: 468 screened 271 not eligible 197 randomized 105 had pre and post treatment urodynamics G1: 33 G2: 35 G3: 37 N at follow-up: NA Age, yrs ± SD: G1: 65.3 ± 4.5 G2: 67.9 ± 7.9 G3: 67.6 ± 7.7 Race/ethnicity, %: Black: 2 White: 98 Women: 100% Parity mean ± SD: G1: 3.1 ± 1.7 G2: 2.1 ± 1.3 G3: 2.3 ± 1.5 | Inclusion criteria: •Community-dwelling women at least age 55 •Ambulatory •At least 2 urge accidents per week by baseline bladder diary •Urge incontinence as predominant pattern •Urodynamic evidence of bladder dysfunction Exclusion criteria: •Continual leakage •Postvoid residual urine volume >200mL •Uterine prolapse past the introitus •Narrow-angle glaucoma •Unstable angina •Decompensated congestive heart failure •Hx of malignant arrhythmias •MMSE <20 (Dementia) | Voids per day, mean ± SD: G1: 10.0 G2: 10.9 G3: 10.0 Cystometry at baseline: First desire to void, mL ± SD: G1: 97.1 ± 50.7 G2: 101.1 ± 62.1 G3: 124.6 ± 73.7 Strong desire to void, mL ± SD: G1: 188.5 ± 93.1 G2: 212.1 ± 86.7 G3: 222.3 ± 87.0 Bladder capacity, mL ± SD: G1: 288.3 ± 117.0 G2: 308.7 ± 93.7 G3: 328.9 ± 107.6 | Voids per day, mean ± SD: G1: 8.2 G2: 8.8 G3: 9.7 DI on UDS, n (%) +Baseline DI/+DI post-treatment G1: 7 (21.2) G2: 1 (2.9) G3: 5 (13.5) DI on UDS, n (%) +Baseline DI/−DI post-treatment G1: 1 (3.0) G2: 7 (20.0) G3: 7 (18.9) DI on UDS, n (%) −Baseline DI/+DI post-treatment G1: 3 (9.1) G2: 3 (8.6) G3: 3 (8.1) DI on UDS, n (%) −Baseline DI/−DI post-treatment G1: 22 (66.7) G2: 24 (68.6) G3: 22 (59.5) Cystometry post-treatment: First desire to void, mL ± SD: G1: 115.9 ± 64.9 G2: 145.6 ± 74.0 G3: 133.5 ± 59.6 Strong desire to void, mL ± SD: G1: 228.9 ± 106.4 G2: 282.0 ± 93.2 G3: 230.1 ± 78.8 Bladder capacity, mL ± SD: G1: 305.6 ± 117.9 G2: 377.6 ± 92.1 G3: 323.0 ± 109.0 Cystometry change: First desire to void, mL: G1: 18.8 G2: 44.4 G3: 8.9 P = 0.149 Strong desire to void, mL: G1: 40.5 G2: 69.9 G3: 7.8 P = 0.018 Bladder capacity, mL: G1: 17.3 G2: 68.9 G3: −6.0 P = 0.000 Standardized estimates of direct and mediated effects of treatment: G1 v G3: Total effect: 0.28* Direct effect: 0.23 Mediated Effect: 0.05 G2 v G3: Total Effect: 0.34* Direct Effect: 0.30* Mediated Effect: 0.04 *P < 0.01 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to follow up: + Drop-out rates: + Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of follow up: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Herschorn et al., 2004 Country and setting: Canada; Family medicine and urology clinics Enrollment period: June 2000 to December 2001 Funding: Pharmacia Pfizer Canada Author industry relationship disclosures: NR | Design: RCT Intervention: Health education with tolterodine vs. tolterodine alone Groups: G1: Health education with tolterodine G2: Tolterodine alone N at enrollment: G1: 39 G2: 45 N at follow-up, 5 weeks: G1: 37 G2: 40 N at follow-up, 10 weeks: G1: 35 G2: 32 N at follow-up, 16 weeks: G1: 34 G2: 31 Age, yrs ± SD: G1: 65.7 ± 14.5 G2: 63.1 ± 15.7 Race/ethnicity: NR Women, %: G1: 92.3 G2: 84.4 Parity: NR | Inclusion criteria: •Age ≥ 50 •Symptoms of OAB •Attend investigators’ practice •Normal cognitive function •Able to read English Exclusion criteria: •Enrollment in another clinical trial •Interstitial cystitis •UTI •Already taking tolterodine | Duration of OAB, yrs ± SD: G1: 8.7 ± 11.0 G2: 8.7 ± 10.8 Mild bladder problems, n (%): G1: 13 (33.3) G2: 13 (28.9) Moderate bladder problems, n (%): G1: 19 (48.7) G2: 28 (62.2) Severe bladder problems, n (%): G1: 7 (18.0) G2: 4 (8.9) Obtained prescription, n (%): G1: 38 (97.4) G2: 37 (82.2) P < 0.05 Intends to fill prescription, (%): G1: 0 (0) G2: 6 (7.5) | Change in incontinence episodes/wk, mean ± SD: G1: −7.72 ± 21.16 G2: −10.24 ± 19.56† Change in voids/d, mean ± SD: G1: −1.82 ± 3.41 G2: −2.18 ± 4.89 P = NR Change in nocturnal voids, mean ± SD: G1: −0.44 ± 1.13† G2: −0.07 ± 0.91 No change in bladder problem severity, n (%): G1: 14 (42.4) G2: 20 (66.7) Improved bladder problem severity, n (%): G1: 15 (45.4)† G2: 6 (20) Worsened bladder problem severity, n (%): G1: 4 (12.1) G2: 4 (13.3) Compliance, 10 weeks, %: G1: 41 G2: 38 P > 0.05 Compliance, 16 weeks, %: G1: 39 G2: 31 P > 0.05 Continued or started non-drug OAB treatment, 16 weeks, %: G1: 82 G2: 53 P > 0.05 Stopped non-drug OAB treatments, %: G1: 12.8 G2: 28.9 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: − Masking: − Pt selection criteria: + Loss to followup: − Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: NR Baseline characteristics: − Length of followup: ++ Measurement methods: + Measurement reliability: − Intervention description: +
Author: Jarvis et al., 1980 Country and setting: UK, Hospital Enrollment period: NR Funding: NR Author industry relationship disclosures: NR | Design: RCT Intervention: Behavioral: 1) rationale explained 2) pt instructed to pass urine at specific intervals during the day 3) pt encouraged to maintain usual fluid intake and chart fluid balance 4) pt introduced to someone successfully treated by the drill Groups: G1: Bladder drill G2: Control (told they should now be able to hold urine 4 hrs and sent home) N at enrollment: G1: 30 G2: 30 N at follow-up: G1: 30 G2: 30 Women, %: 100 Age, range: 27–79 Race/ethnicity: NR | Inclusion criteria: •Women •Diagnosis of DI by pressure flow studies •Not taking medications known to affect urinary tract function Exclusion criteria: •Co-existing genuine SUI | UUI, n: G1: 30 G2: 30 SUI, n: G1: 21 G2: 21 Urgency, n: G1: 30 G2: 30 Diurnal frequency, n: G1: 30 G2: 30 Nocturnal frequency, n: G1: 27 G2: 25 | Continent and symptom-free: G1: 27 G2: 7 P < 0.01 UUI, n: G1: 3 G2: 23 P < 0.01 SUI, n: G1: 3 G2: 16 P < 0.01 Urgency, n: G1: 4 G2: 23 P < 0.01 Diurnal frequency, n: G1: 5 G2: 23 P < 0.01 Nocturnal frequency: G1: 3 G2: 20 P < 0.01 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: − Masking: − Pt selection criteria: − Loss to follow up: ++ Drop-out rates: ++ Power calculation: − Statistical issues: − EXTERNAL VALIDITY: poor Age: + Baseline OAB status: NR Baseline characteristics: − Length of follow up: ++ Measurement methods: − Measurement reliability: − Intervention description:−
Author: Jarvis et al., 1981 Country and setting: UK, Academic medical center Enrollment period: NR Funding: NR Author industry relationship disclosures: NR | Design: RCT Intervention: Inpatient bladder drill vs. outpatient drug therapy Groups: G1: Inpatient bladder drill G2: Flavoxate hydrochloride 200 mg t.i.d. and imipramine 25 mg t.i.d. x 4 wks N at enrollment: G1: 25 G2: 25 N at follow-up: G1: 25 G2: 25 Women, %: 100 Age, mean ± SD (range): G1: 47 ± 15.4 (17–78) G2: 46 ± 12.8 (17–65) | Inclusion criteria: • Women • UDS-diagnosed detrusor instability Exclusion criteria: • DM • Neurological abnormalities • UTIs • Taking a drug suspected of affecting lower urinary tract function • Genuine stress incontinence | UUI, n: G1: 25 G2: 25 SUI, n: G1: 19 G2: 17 Urgency, n: G1: 25 G2: 25 Frequency, n: G1: 25 G2: 25 Nocturia, n: G1: 21 G2: 19 Duration of symptoms (years), mean ± SD (range): G1: 4.3 ± 2.7 (1–15) G2: 5.4 ± 3.2 (1–20) Bladder volume (mL), first sensation, mean: G1: 87 G2: 79 Max cystometric capacity (mL), mean: G1: 381 G2: 353 | UUI, n: G1: 4 G2: 11 SUI, n: G1: 1 G2: 9 Urgency, n: G1: 4 G2: 11 Frequency, n: G1: 6 G2: 12 Nocturia, n: G1: 4 G2: 13 Continent, n (%): G1: 21 (84) G2: 14 (56) P < 0.05 Symptom-free, n (%): G1: 19 (76) G2: 12 (48) P < 0.05 Bladder volume (mL), first sensation, mean: G1: 152 G2: 140 Max cystometric capacity (mL), mean: G1: 470 G2: 446 Adverse events, drug therapy, n:* Dizziness: 8 Headache: 6 Dry mouth: 6 Nausea: 4 Drowsiness: 2 Vomiting: 1 Discontinued due to AEs, n: Dizziness: 1 Headache: 1 Vomiting: 1 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: − Masking: − Pt selection criteria: + Loss to follow up: ++ Drop-out rates: − Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Lauti et al., 2008 Country and setting: New Zealand, Academic Enrollment period: February 2003 to July 2003 Funding: University of Otago Author industry relationship disclosures: None | Design: RCT pilot study, unmasked Intervention: Oxybutynin vs. bladder retraining vs. combination therapy Groups: G1: Oxybutynin 2.5 mg/day (daily dose could be increased by 2.5 mg every 5 days to a maximum of 15 mg/day) G2: Bladder retraining G3: Combination therapy N screened: 120 N at enrollment: G1: 21 G2: 16 G3: 19 N at 3 month follow-up: G1: 18 G2: 16 G3: 12 N at 12 month follow-up: G1: 16 G2: 14 G3: 12 Age, mean ± SD: G1: 53.8 ± 14.8 G2: 63.9 ± 17.2 G3: 47.6 ± 16.3 Race/ethnicity: NR Women, %: Total: 100 Parous, %: G1: 81 G2: 62.5 G3: 73.7 | Inclusion criteria: • Age > 18 • Predominant UUI Exclusion criteria: • Predominant SUI • Contraindications to anticholinergic drugs • Current UTI • Neurological disease • Psychiatric disorder • Untreated co-existing pelvic organ prolapse below the hymenal ring • Obstructed voiding • Functional-reversible cause of incontinence • Inability to toilet independently • Limited fluency of written/spoken English • Current or recent use of any of the trial interventions | Urgency episodes/day, mean ± SD: G1: 3.8 ± 2.7 G2: 3.1 ± 2.2 G3: 3.5 ± 2.0 Incontinence episodes/day, mean ± SD: G1: 2.2 ± 1.5 G2: 1.0 ± 1.1 G3: 1.8 ± 1.6 Nocturia episodes/day, mean ± SD: G1: 1.1 ± 1.0 G2: 1.4 ± 1.0 G3: 0.8 ± 0.7 Voids per day, mean ± SD: G1: 7.8 ± 2.8 G2: 8.0 ± 1.7 G3: 8.4 ± 2.5 OAB-q total HRQoL, mean ± SD: G1: 73.1 ± 17.4 G2: 69.5 ± 24.6 G3: 71.6 ± 21.5 OAB-q severity, mean ± SD: G1: 47.0 ± 16.2 G2: 42.3 ± 17.7 G3: 45.9 ± 18.7 OAB-q coping, mean ± SD: G1: 72.0 ± 21.6 G2: 66.2 ± 31.7 G3: 73.8 ± 26.2 OAB-q concern, mean ± SD: G1: 68.2 ± 19.0 G2: 68.8 ± 27.6 G3: 63.8 ± 29.2 OAB-q sleep, mean ± SD: G1: 63.1 ± 28.7 G2: 59.8 ± 29.9 G3: 55.1 ± 27.6 OAB-q social, mean ± SD: G1: 92.5 ± 14.6 G2: 85.4 ± 19.9 G3: 92.8 ± 18.6 SF-12 quality of life, physical, mean ± SD: G1: 49.0 ± 9.6 G2: 41.7 ± 11.5 G3: 46.2 ± 10.6 SF-12 quality of life, mental, mean ± SD: G1: 49.1 ± 9.3 G2: 53.1 ± 8.8 G3: 46.3 ± 8.3 | Urgency episodes/day, 3 mos, mean ± SD: G1: 2.2 ± 1.8 G2: 1.5 ± 2.1 G3: 1.7 ± 1.8 Urgency episodes/day, 12 mos, mean ± SD: G1: 2.3 ± 2.5 G2: 1.9 ± 2.1 G3: 2.0 ± 1.1 Incontinence episodes/day, 3 mos, mean ± SD: G1: 0.8 ± 0.8 G2: 0.1 ± 0.3 G3: 0.6 ± 0.8 Incontinence episodes/day, 12 mos, mean ± SD: G1: 0.9 ± 0.0 G2: 0.9 ± 1.0 G3: 0.8 ± 0.7 Nocturia episodes/day, 3 mos, mean ± SD: G1: 1.0 ± 0.5 G2: 0.8 ± 0.7 G3: 0.6 ± 0.5 Nocturia episodes/day, 12 mos, mean ± SD: G1: 1.0 ± 0.9 G2: 1.2 ± 0.6 G3: 0.7 ± 0.7 Voids/day, 3 mos, mean ± SD: G1: 6.7 ± 1.8 G2: 6.3 ± 1.6 G3: 6.7 ± 2.2 Voids/day, 12 mos, mean ± SD: G1: 7.2 ± 1.1 G2: 6.8 ± 1.4 G3: 7.6 ± 1.5 OAB-q total HRQoL, 3 mos, mean ± SD: G1: 82.3 ± 16.1 G2: 89.6 ± 9.4 G3: 91.8 ± 7.4 OAB-q total HRQoL, 12 mos, mean ± SD: G1: 87.9 ± 11.6 G2: 81.6 ± 19.3 G3: 88.9 ± 9.9 OAB-q severity, 3 mos, mean ± SD: G1: 37.2 ± 22.0 G2: 16.8 ± 12.0 G3: 21.6 ± 10.9 OAB-q severity, 12 mos, mean ± SD: G1: 24.6 ± 10.6 G2: 33.1 ± 16.6 G3: 21.9 ± 14.8 OAB-q coping, 3 mos, mean ± SD: G1: 79.2 ± 22.1 G2: 91.6 ± 9.5 G3: 92.7 ± 9.4 OAB-q coping, 12 mos, mean ± SD: G1: 89.2 ± 13.7 G2: 81.5 ± 23.7 G3: 90.5 ± 10.0 OAB-q concern, 3 mos, mean ± SD: G1: 78.6 ± 18.0 G2: 87.7 ± 14.5 G3: 90.2 ± 12.4 OAB-q concern, 12 mos, mean ± SD: G1: 85.3 ± 15.5 G2: 81.7 ± 19.7 G3: 85.2 ± 13.4 OAB-q sleep, 3 mos mean ± SD: G1: 77.7 ± 24.9 G2: 81.3 ± 14.6 G3: 85.0 ± 19.6 OAB-q sleep, 12 mos, mean ± SD: G1: 79.9 ± 18.3 G2: 72.0 ± 24.5 G3: 83.2 ± 18.4 OAB-q social, 3 mos, mean ± SD: G1: 96.4 ± 9.7 G2: 95.6 ± 7.0 G3: 98.9 ± 1.9 OAB-q social, 12 mos, mean ± SD: G1: 97.3 ± 7.1 G2: 91.9 ± 14.2 G3: 97.3 ± 6.9 SF-12 quality of life, physical G1: 50.6 ± 8.0 G2: 42.1 ± 12.7 G3: 48.4 ± 10.8 SF-12 quality of life, physical, 12 mos, mean ± SD: G1: 50.0 ± 7.3 G2: 45.1 ± 13.9 G3: 45.3 ± 13.4 SF-12 quality of life, mental, 3 mos, mean ± SD: G1: 50.4 ± 9.6 G2: 51.2 ± 9.5 G3: 46.7 ± 7.6 SF-12 quality of life, mental, 12 mos, mean ± SD: G1: 49.6 ± 7.5 G2: 50.1 ± 10.7 G3: 50.6 ± 8.4 Dry mouth, n (%): G1: 3 (21) G2: 5 (46) G3: 5 (42) Headaches, n (%): G1: 6 (43) G2: 1 (11) G3: 7 (58) Dizziness, n (%): G1: 4 (29) G2: 2 (20) G3: 3 (25) Constipation, n (%): G1: 3 (21) G2: 3 (27) G3: 3 (27) Fatigue, n (%): G1: 9 (64) G2: 5 (46) G3: 7 (64) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Method and blinding: − Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: + Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Macaulay et al., 1987 Country and setting: UK, Specialty treatment center Enrollment period: NR Funding: Wellcome Trust, trustees of St. George’s Hospital Author industry relationship disclosures: NR | Design: RCT Intervention: Brief eclectic psychotherapy, bladder training or medication Groups: G1: Psycho-therapy G2: Bladder drill G3: Propantheline N at enrollment: G1: 19 G2: 16 G3: 15 N at follow-up: G1: 18 G2: 15 G3: 14 Women, %: 100 Age: NR Race/ethnicity: NR Follow-up: 3 months | Inclusion criteria: • Previous completion of survey on psych conditions w/OAB • Detrusor instability on UDS or sensory urgency Exclusion criteria: NR | Detrusor instability, n: G1: 10 G2: 8 G3: 8 Sensory urgency, n: G1: 9 G2: 8 G3: 7 Voids/day, mean: G1: NR G2: NR G3: 10.8 Bladder capacity (mL), mean: G1: 393 G2: NR G3: 323 Bladder volume (mL), first sensation, mean: G1: 107 G2: 110 G3: 70 Detrusor pressure rise (cm H_2_O), mean: G1: NR G2: 45.5 G3: NR | Voids/day, mean: G1: NR G2: NR G3: 8.3 G3/BL: P < 0.005 Bladder capacity (mL), mean: G1: 414 G2: NR G3: 368 G1/BL: P = NS G3/BL: P = NS Bladder volume (mL), first sensation, mean: G1: 142 G2: 150 G3: 137 G1/BL: P = NS G2/BL: P < 0.05 G3/BL: P = 0.06 Detrusor pressure rise (cm H_2_O), mean: G1: NR G2: 29.5 G3: NR G2/BL: P < 0.05 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: − Masking: − Pt selection criteria: − Loss to follow up: ++ Drop-out rates: ++ Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: −, NR Baseline OAB status: NR Baseline characteristics: − Length of follow up: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Mattiason et al., 2003 Country and setting: Sweden, Denmark, Norway (Tolterodine Scandinavian Study Group) Enrollment period: October 1999 to December 2000 Funding: Pharmacia Corp Author industry relationship disclosures: NR | Design: RCT, single-blinded (balanced blocks of 4, computerized randomization list) Intervention: Tolterodine 2mg b.i.d. ± bladder training (BT); Tolterodine dosage could be decreased to 1 mg P.O. b.i.d. during the first 2 wks if intolerable SE; BT taught with a written handout Groups: G1: Tolterodine + BT × 24 wks G2: Tolterodine × 24 wks N at enrollment: Total: 505 N at follow-up: G1: 244 G2: 257 N Completed treatment: G1: 77% G2: 79% Total: 74% Women, n (%) G1: 177 (73) G2: 201 (78) Age, median (range): G1: 62 (19, 86) G2: 63 (22, 86) Race/ethnicity: NR Follow-up: 24 weeks | Inclusion criteria: • Age ≥ 18 • ≥ 8 voids/day and urinary urgency (± UUI) as determined by 1 wk bladder diary • With or without UUI • Women of reproductive age had to be using reliable birth control Exclusion criteria: • Contraindication to antimuscarinic therapy • Use of electrostimulation therapy or BT within prior 3 mo • Indwelling catheter or intermittent catheterization • Pregnancy or lactation • Use of anticholinergic agents or concomitant treatment for OAB (estrogen permitted) | Urgency episodes/day, mean (range): G1: 6.0 (0, 23.0) G2: 6.6 (0, 34.3) Incontinence episodes/day, mean (range): G1: 2 (0.3, 20.3) G2: 2.3 (0.3, 16.3) Voids/day, mean (range): G1: 10.3 (7.3, 27.6) G2: 10.6 (7.7, 24.6) Duration of symptoms > 5 years, n (%): G1: 120 (49) G2: 124 (48) Previous drug therapy for OAB, n (%): G1: 40 (160 G2: 35 (14) Previous surgery affecting lower urinary tract, n (%): G1: 28 (11.5) G2: 30 (12) Symptoms caused at least moderate problems, %: G1: 92 G2: 93 | Urgency episodes/day, median % change (IQR): G1: −38 (−76.7, −14.1) G2: −38 (−68.7, −8.0) G1/G2: P = 0.75 Incontinence episodes/day, median IQR% change; n=301: G1: −87 (−100, −20) G2: −81 (−100, −41.8) G1/G2: P = 0.28 Voids/day, median % change (IQR): G1: −33 (−42.3, 21.3) G2: −25 (−38.8, −13.0) G1/G2: P < 0.001 Voided volume (mL), median % change (IQR): G1: 31.5 (13.3, 56.2) G2: 20 (3.1, 45.4) G1/G2: P <0.001 Symptoms are “minor or less”, %: G1: 66.5 G2: 61.5 Overall improvement in symptoms, %: G1: 76 G2: 71 Worsening of symptoms, %: G1: 3 G2: 5 Dry mouth, n (%): G1: 76 (31) G2: 90 (35) Headache, n (%): G1: 15 (6) G2: 21 (8) Constipation, n (%): G1: 7 (3) G2: 14 (5) ≥ 1 SE, n (%): G1: 158 (65) G2: 177 (69) G1/G2: P = NS Withdrawal due to, %: AE: 15 Withdrawal due to lack of efficacy: 3 Withdrawal of consent: 2 Protocol violations: 1 Completed treatment: G1: 77% G2: 79% | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to follow up: − Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of follow up: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Millard et al., 1983 Country and setting: Australia, Hospital Enrollment period: NR Funding: NR Author industry relationship disclosures: NR | Design: Report of hospital-based results Intervention: All patients initially hospitalized for 5–14 days then assigned to a Frewen-type bladder training program or biofeedback, each lasting 3 months. Adjunctive therapy* was used when patients did not show improvement. Groups: NR N at enrollment: 59 N at follow-up: 59 Women, %: 100 N at follow-up: 39 Age, mean (range): 49 (14–74) Race/ethnicity: NR | Inclusion criteria*: • Men, women or children with frequency, urgency, nocturia and urge incontinence Exclusion criteria: • Neurological lesions | Frequency, n: 59 Nocturia, n: 37 UUI, n: 42 MUI, n: 24 Enuresis, n: 12 Giggle, n: 9 Urodynamic status, n: Unstable bladder: 38 Unstable bladder & bladder neck incompetence: 6 Sensory urgency: 12 Sensory urgency & bladder neck incompetence: 3 Duration of symptoms (years), mean: 11.9 | Results, patients with unstable bladder, n: Cure: 18 Significant improvement: 10 Minor improvement: 2 Failure: 8 Results, patients with unstable bladder & bladder neck incompetence, n: Cure: 0 Significant improvement: 3 Minor improvement: 1 Failure: 0 Results, patients with sensory urgency, n: Cure: 7 Significant improvement: 4 Minor improvement: 1 Failure: 0 Results, patients with sensory urgency & bladder neck incompetence, n: Cure: 0 Significant improvement: 0 Minor improvement: 0 Failure: 3 Bladder Capacity (mL), by result, patients with unstable bladder, mean change: Cure: 149 Significant improvement: 87 Minor improvement: 95 Failure: 73 Bladder Capacity (mL) by result, patients with sensory urgency, mean change: Cure: 83 Significant improvement: 115 Minor improvement: 127 Failure: NA Voiding frequency (hours), by result, patients with unstable bladder, initial/final: Cure: 1.9/4.8 Significant improvement: 1.8/3.2 Minor improvement: 1.0/4.0 Failure: 1.4/3.3 Voiding frequency (hours), by result, patients with sensory urgency, initial/final: Cure: 1.7/3.8 Significant improvement: 1.0/3.4 Minor improvement: 3.3/4.0 Fail: NA | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: − Loss to follow up: ++ Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of follow up: + Measurement methods: − Measurement reliability: + Intervention description: +
Author: Sand et al., 2007 Country and setting: US, Multicenter, 327 sites (141 Urology 141, 96 Primary care, 43 Ob-Gyn, 17 Geriatric Med) Enrollment period: NR Funding: Watson Laboratories, Inc Author industry relationship disclosures: 7 of 7 Allergan (1) Astellas (1) Esprit (1) GlaxoSmithKline (2) GSK (1) GTx (1) Indevus-Esprit (1) Lilly (1) Novartis (3) Ortho-McNeil (1) Ortho Urology (1) Pfizer (4) Sanofi (1) USB (1) Watson (6) | Design: RCT, open-label (case series for drug, RCT for educational materials) Intervention: Oxybutynin transdermal system 3.9 mg/day, twice weekly patch for up to 6 months with “standard instruction” or with “educational intervention”. Groups: G1: Standard instructions G2: Educational intervention (educational booklet, OAB newsletters, dosing reminders, calendar reminders, bladder diary) N at enrollment: Total: 2,878 G1: 1,282 G2: 1,596 Women, %: 87.2 Age, yrs ± SD: 62.5 ± 14.8 Race/ethnicity, %: White: 83.6 African American: 9.9 Hispanic: 4.8 Asian: 1.2 Other: 0.5 Follow-up: 6 months | Inclusion criteria: • Age ≥18 • UUI, urinary urgency or frequency • Willing to discontinue all prescription and OTC medications for OAB • Capable of completing QoL questionnaires without assistance • Negative pregnancy test & medically acceptable contraceptive Exclusion criteria: • Contraindications to oxybutynin • Reversible etiologies for OAB • Prior treatment with Oxytrol • Long-term care facilities and nursing homes | KHQ, UUI severity item score, %: A lot: 38.1 Moderately: 31.3 A little: 20.5 Omitted, N/A: 10.1 KHQ, urgency severity item score, %: A lot: 49.2 Moderately: 30.3 A little: 14.8 Omitted, N/A: 5.6 KHQ, frequency severity item score, %: A lot: 59.3 Moderately: 32.5 A little: 7.2 Omitted, N/A:1.0 KHQ, nocturia severity item score, %: A lot: 47.3 Moderately: 33.5 A little: 16.7 Omitted, N/A: 2.4 History of OAB, years, %: <1 year: 12.0 1–2 years: 18.5 2–4 years: 23.1 ≥ 4 years: 46.4 OAB Severity: No problem: 1.8 Very minor: 4.6 Minor: 15.5 Moderate: 33.0 Severe: 28.4 Many severe problems: 16.7 Previous OAB treatments, n (%): 0: 43.4 1: 38.7 2: 13.1 3: 2.9 4: 1.9 KHQ, general health perception, mean ± SD: 28.2 ± 19.8 KHQ, incontinence Impact, mean ± SD: 69.3 ± 27.4 KHQ, symptom severity, mean ± SD: 55.9 ± 20.5* KHQ, role limitations, mean ± SD: 45.1 ± 31.0 KHQ, physical limitations, mean ± SD: 46.7 ± 31.6 KHQ, social limitations, mean ± SD: 25.6 ± 28.3 KHQ, emotions, mean ± SD: 30.0 ± 29.2 KHQ, personal relationships, mean ± SD: 20.6 ± 29.5*** KHQ, sleep/energy, mean ± SD: 54.2 ± 27.3 KHQ, severity (coping) measures, mean ± SD: 47.9 ± 26.4 | KHQ, UUI severity item score, %: A lot: 21.3 Moderately: 29.5 A little: 31.6 Omitted, N/A: 17.7 KHQ, urgency severity item score, %: A lot: 27.3 Moderately: 33.8 A little: 27.3 Omitted, N/A: 11.5 KHQ, frequency severity item score, %: A lot: 33.5 Moderately: 45.2 A little: 18.7 Omitted, N/A: 2.6 KHQ, nocturia severity item score, %: A lot: 27.5 Moderately: 35.4 A little: 31.3 Omitted, N/A: 5.7 KHQ, general health perception, mean ± SD (% improvement): −1.2 ± 17.4 (−4.3) KHQ, incontinence Impact, mean ± SD (% improvement): −13.5 ± 29.5 (−19.5) KHQ, symptom severity, mean ± SD (% improvement): −12.4 ± 24.8 (−22.2)*** KHQ, role limitations, mean ± SD (% improvement): −13.3 ± 29.2 (−29.5) KHQ, physical limitations, mean ± SD (% improvement): −11.7 ± 29.9 (−25.1) KHQ, social limitations, mean ± SD (% improvement): −6.7 ± 23.7 (−26.2) KHQ, emotions, mean ± SD (% improvement): −8.8 ± 25.4 (−29.3) KHQ, personal relationships, mean ± SD (% improvement): −6.0 ± 23.5 (−29.1)*** KHQ, sleep/energy, mean ± SD (% improvement): −11.2 ± 24.1 (−20.7) KHQ, severity (coping) measures, mean ± SD (% improvement): −8.6 ± 21.3 (−18.0) Side effects, application site, %: Total: 14.0 Pruritis: 4.9 Erythema: 4.6 Dermatitis: 4.4 Irritation: 3.2 Other: 2.0 Side effects, %: Rash: 3.0 Dry mouth: 2.6 Pruritis: 2.6 Skin irritation: 2.1 Withdrew due to AEs, %: 21.3 Withdrew: 1452 (50.5%) Adverse events, %: 21.3 Withdrawn consent, %: 7.5 Requirement for alternative therapy, %: 7.4 Loss to follow-up, %: 7.2 Noncompliance, %: 5.6 Administrative decision, %: 0.7 Ineligible, %: 0.4 Death, %: 0.1 No reason given, %: 0.3 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: NA Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Song, et al., 2006 Country and setting: Korea, Medical Center Enrollment period: May 2001 to April 2002 Funding: NR Author industry relationship disclosures: NR | Design: RCT Intervention: Bladder training (BT) vs. Tolterodine vs. BT + Tolterodine Groups: G1: BT x 12 wks G2: Tolterodine 2 mg bid x 12 wks G3:Tolterodine 2 mg bid + BT x 12 wks N at enrollment: G1: 46 G2: 47 G3: 46 N at follow-up: G1: 26 G2: 32 G3: 31 Women, %: 100 Age, mean ± SD: G1: 45.73 ± 12.68 G2: 48.41 ± 9.38 G3: 45.42 ± 9.54 Race/ethnicity, %: Korean: 100 | Inclusion criteria: • Age ≥ 18 • ≥ 8 voids/day • Urge with or without incontinence • Symptom duration ≥ 3 months • No prior history of treatment for OAB Exclusion criteria: • Active urinary tract infection • Clinically significant SUI • Bladder outlet obstruction • Interstitial cystitis • Glaucoma • Megacolon • Maximal urine flow rate of < 10 mL/sec • Postvoid residual volume > 30% of the total amount voided on uroflowmetry | Voids/day, mean ± SD: G1: 10.93 ± 2.14 G2: 11.63 ± 2.57 G3: 11.90 ± 1.51 Nocturia episodes/day, mean ± SD: G1: 1.45 ± 1.14 G2: 1.72 ± 1.04 G3: 1.96 ± 1.49 Urgency, mean score ± SD: G1: 2.58 ± 1.30 G2: 2.81 ± 0.74 G3: 3.00 ± 1.10 Maximum flow rate (mL/s), mean ± SD: G1: 20.35 ± 8.44 G2: 22.56 ± 4.94 G3: 21.19 ± 4.96 Residual urine (mL), mean ± SD: G1: 9.08 ± 22.56 G2: 7.59 ± 12.39 G3: 6.42 ± 10.16 Symptom duration (years), mean ± SD: G1: 6.44 ± 6.84 G2: 4.54 ± 5.15 G3: 4.10 ± 3.99 | Voids/day, mean (% decrease) G1: 8.1 (25.9%)* G2: 8.1 (30.2%)* G3: 7.9 (33.5%)* G3/G1: P < 0.05 Nocturia episodes/day, mean (% reduction): G1: 0.6 (56.1%)* G2: 0.6 (65.4%)* G3: 0.6 (66.3%)* Urgency, mean score (% reduction): G1: 1.4 (44.8%)* G2: 1.1 (62.2%)* G3: 1.2 (60.2%)* G3/G1: P = 0.021 G2/G1: P = 0.017 G2/G3: P = NS Satisfaction, mean score (% improved): G1: 1.5 (53.9) G2: 1.4 (63.0) G3: 1.3 (71.0) Dry mouth, n (%): G1: 0 (0.0) G2: 7 (21.9) G3: 9 (28.9) Hesitancy, n (%) G1: 0 (0.0) G2: 3 (9.4) G3: 2 (6.5) Decreased appetite/constipation, n (%): G1: 0 (0.0) G2: 2 (6.3) G3: 2 (6.5) Headache, n (%): G1: 0 (0.0) G2: 1 (3.1) G3: 0 (0.0) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: − Pt selection criteria: + Loss to follow up: − Drop-out rates: + Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of follow up: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Szonyi et al., 1995 Country and setting: UK Enrollment period: NR Funding: Smith & Nephew Pharmaceuticals Ltd Author industry relationship disclosures: NR | Design: RCT Intervention: Oxybutynin + bladder training vs. placebo + bladder training Groups: G1: Oxybutynin 2.5 mg bid with dose titration on days 29 and 43 plus bladder training G2: Placebo + bladder training N at enrollment: G1: 30 G2: 30 N at follow-up: G1:16 G2: 23 Women, n (%): 56 (93) Age, mean ± SD: 82.2 ± 6.06 Race/ethnicity: NR Weight (kg), mean ± SD: 67.4 ± 14.92 | Inclusion criteria: • Age > 70 • Frequency, urgency and UUI • Mobile • Able to keep diary Exclusion criteria: • UTI • Hepatic or renal disease • Glaucoma • Uncontrolled diabetes • Taking imipramine or propantheline | | Voids/2 weeks, median change (95% CI): G1/G2: 577 (−27.0, 6.0) P = 0.0025 Nocturia episodes/2 weeks, median change (95% CI): G1/G2: −6 (−5, 7.0) Daytime incontinence episodes/2 weeks, median change (95% CI): G1 vs. G2: −9.5 (−11.0, 3.0) Nocturia episodes/2 weeks, median change (95% CI): G1/G2: −1.0 (−3.0, 2.0) Patient assessment of benefit, %: 29 days: G1: 86 G2: 55 P = 0.02 43 days: G1: 71 G2: 59 P = 0.41 57 days: G1: 79 G2: 55 P = 0.09 Patient response, 29 days, n: Cure: G1: 1 G2: 0 Significant improvement: G1: 15 G2: 8 Marginal improvement: G1: 7 G2: 8 No change: G1: 5 G2: 13 Patient response, 57 days, n: Cure: G1: 4 G2: 3 Significant improvement: G1: 14 G2: 8 Marginal improvement: G1: 3 G2: 4 No change: G1: 7 G2: 14 Dry mouth, %: G1: 93 G2: 86 Blurred vision, %: G1: 50 G2: 59 Heartburn, %: G1: 57 G2: 45 Constipation, %: G1: 50 G2: 45 Dry skin, %: G1: 50 G2: 59 Poor compliance (< 75% of tablets), %: G1: 20 G2: 20 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to follow up: − Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: + Length of follow up: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Wang et al., 2004 Country and setting: Taiwan, NR Enrollment period: July 2001 to December 2002 Funding: National Science Council, Taiwan Author industry relationship disclosures: NR | Design: RCT Intervention: Pelvic floor muscle training (PFMT), biofeedback-assisted PFMT (BAPFMT), electrical stimulation (ES) Groups: G1: PFMT per PERFECT score G2: BAPFMT per PERFECT score G3: ES using biphasic symmetric probe current w/10-Hz freq, 400-microsec pulse width, 10/5 duty cycle, varying intensity N at enrollment: G1: 40 G2: 38 G3: 42 N at follow-up: G1: 34 G2: 34 G3: 35 Women: 100% Age, mean ± SD: G1: 50.09 ± 15.85 G2: 52.32 ± 12.68 G3: 55.74 ± 12.53 Race/ethnicity: NR BMI, kg/m^2^ ± SD: G1: 22.69 ± 3.32 G2: 23.70 ± 3.90 G3: 23.93 ± 3.21 Parity, mean ± SD: G1: 2.47 ± 1.44 G2: 2.91 ± 1.86 G3: 3.69 ± 1.75 Menopausal, n (%) G1: 21 (61.76) G2: 17 (50) G3: 8 (22.86) | Inclusion criteria: • Female • Age 16–75 • OAB symptoms for > 6 months • Voids/day ≥ 8 • UUI/day ≥ 1 Exclusion criteria: • Anticholinergic medications • Tricyclic antidepressants • Treatment with pelvic-floor exercises • Treatment with bladder training • Repair of pelvic prolapse • Pregnancy • Deafness • Neurologic disorders • DM • Pacemaker or IUD use • Genital prolapse > stage II by ICS • Residual urine > 100 mL • UTI | Incontinence episodes/day, mean ± SD: G1: 0.86 ± 1.80 G2: 0.92 ± 1.77 G3: 2.09 ± 2.96 Urine leakage during former pregnancy, no (%): G1: 7 (20.59) G2: 3 (8.83) G3: 3 (8.57) | UUI symptoms resolved, n (%): G1: 10 (30.3) G2: 13 (38.24) G3: 14 (40) UUI symptoms modified, n (%): G1: 3 (6.06) G2: 4 (11.76) G3: 4 (11.43) UUI symptoms unchanged, n (%): G1: 21 (63.64) G2: 17 (50) G3: 17 (48.6) Incontinence episodes/day, mean ± SD: G1: 0.73±1.82 G2: 0.70±1.80 G3: 1.95±2.84 G1/G2/G3: P = 0.016 OAB symptom improvement/cure, %: G1: 38.2 G2: 50.0 G3: 51.4 G1/G2/G3: P = 0.567 Adherence to treatment, median % (range): G1: 0.833 (0.25–1.00) G2: 0.791 (0.58–1.99) G3: 0.750 (0.54–1.00) G1/G2/G3: P = 0.356 Compliance with home program (days), median (range): G1: 8.5 (0–44) G2: 14.5 (0–44) G1/G2: P = 0.636 KHQ, general health perception, mean change ± SD: G1: 14.66 ± 24.57 G2: 12.10 ± 20.28 G3: 16.96 ± 24.58 G1/G2/G3: P = 0.376 KHQ, incontinence impact, mean change ± SD: G1: 6.03 ± 120.82 G2: 37.42 ± 37.11 G3: 47.03 ± 35.45 G1/G2/G3: P = 0.067 KHQ, role limitation, mean change ± SD: G1: 25.86 ± 26.57 G2: 30.64 ± 30.15 G3: 34.52 ± 31.73 G1/G2/G3: P = 0.376 KHQ, physical limitation, mean change ± SD: G1: 25.29 ± 26.58 G2: 33.33 ± 33.88 G3: 28.57 ± 28.99 G1/G2/G3: P = 0.693 KHQ, social limitation, mean change ± SD: G1: 17.05 ± 21.20 G2: 22.76 ± 29.20 G3: 20.84 ± 27.45 G1/G2/G3: P = 0.799 KHQ, personal relationships, mean change ± SD: G1: 2.30 ± 13.89 G2: 10.75 ± 26.37 G3: 3.57 ± 22.39 G1/G2/G3: P = 0.167 KHQ, emotions, mean change ± SD: G1: 19.31 ± 29.68 G2: 22.22 ± 27.82 G3: 46.83 ± 37.33 G1/G2/G3: P = 0.005 G2/G3: P = 0.003 G1/G3: P = 0.007 G2/G1: P = 0.751 KHQ, sleep/energy, mean change ± SD: G1: 18.83 ± 26.18 G2: 26.88 ± 24.60 G3: 38.10 ± 39.51 G1/G2/G3: P = 0.249 KHQ, severity measures, mean change ± SD: G1: 14.71 ± 20.27 G2: 20.65 ± 31.19 G3: 31.23 ± 23.83 G1/G2/G3: P = 0.004 G2/G3: P = 0.029 G1/G3: P = 0.001 G2/G1: P = 0.587 KHQ, total score, mean change ± SD: G1: 50.27 ± 171.42 G2: 185.86 ± 176.57 G3: 180.08 ± 176.03 G1/G2/G3: P = 0.003 G2/G3: P = 0.952 G1/G3: P = 0.004 G2/G1: P = 0.003 Pelvic muscle strength, scale of power: G2/G3: P < 0.001 G1/G3: P < 0.001 Times of fast contraction, mean ± SD: G1: −5.82 ± 5.05 G2: −6.21 ± 4.56 G3: −3.03 ± 4.98 G2/G3: P = 0.007 G1/G3: P = 0.012 Degree of vaginal pressure, mean change ± SD: G1: −36.03 ± 21.79 G2: −38.35 ± 29.62 G3: −8.91 ± 12.83 G2/G3: P < 0.001 G1/G3: P < 0.01 Vaginal pressure, mean % change (range): G1: −78.95 (−522.22, −10.34) G2: −105.0 (−2450 to 79.55) G3: −12.63 (−138.46 to 50) G1/G2/G3: P < 0.001 Vaginal pressure, mean change ± SD: G1: −36.03 ± 21.79 G2: −38.35 ± 29.62 G3: −8.91 ± 12.83 G2/G3: P < 0.001 G1/G3: P < 0.001 G2/G1: P = NS | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: − Pt selection criteria: + Loss to follow up: + Drop-out rates: − Power calculation: + Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of follow up: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Wang et al., 2006 Country and setting: Taiwan; Academic medical center Enrollment period: July 2004 to November 2005 Funding: National Science Council, Taiwan Author industry relationship disclosures: NR | Design: RCT Intervention: Electric Stimulation (ES) vs. Oxybutynin vs. Placebo for 12 weeks Groups: G1: ES: intravaginal electrode; biphasic symmetric pulsed current w/a 10-Hz frequency, 400-millisecond pulse width, 10/5 duty cycle, and varying intensity, 20 min/session, twice weekly G2: Oxybutynin, 2.5 mg t.i.d. G3: Placebo pill t.i.d. N at enrollment: G1: 25 G2: 26 G3: 23 N at follow-up: G1: 24 G2: 23 G3: 21 Age: NR Race/ethnicity: NR | Inclusion criteria: • Female • OAB for ≥ 6 mos • Age 16–80 • Urgency ≥ 4 times per day Exclusion criteria: • Use of anticholinergics or TCAs • Previous treatment with pelvic-floor muscle training, bladder training • Pelvic prolapse repair • Pregnancy • Neurologic disorders • DM • Demand cardiac pacemaker • IUD use • Genital prolapse greater than ICS Stage II • PVR>100 mL • Overt SI • Anti-incontinence surgery • UTI | Warning time, s (range) G1: 41.5 (8–105) G2: 44 (2–215) G3: 65 (26–265 MVV, mL/void (range): G1: 340 (120–450) G2: 310 (130–800) G3: 350 (120–600) Daily voided volume, mL (range) G1: 2160 (1010–2950) G2: 2106 (1560–3153) G3: 2305 (1305–3300) Pads per day (range): G1: 1 (0–4.1) G2: 0 (0–3) G3: 1 (0–4) Urgency (subj): G1: 11.4 (4.0–16.0) G2: 12.1 (5–18) G3: 9.8 (4.2–15.5) Frequency (subj): G1: 12.8 (8.8–16.0) G2: 11.5 (4.3–19.5) G3: 11.5 (6.5–22.8) Nocturia (subj): G1: 1.75 (0–6.5) G2: 0 (0–2.5) G3: 0.65 (0–3.1) UI (subj): G1: 1 (0–2) G2: 0 (0–2) G3: 1 (0–2) | Warning time, s (range) G1: 72 (32–633) G2: 54.5 (138–850) G3: 66.5 (26–219) P(G1–G3) < 0.001 MVV, mL/micturition (range): G1: 355 (150–550) G2: 336.5 (138–850) G3: 340 (160–600) P(G1–G3) = 0.035 Voided volume/d, mL (range) G1: 2270 (1210–3106) G2: 2100 (1619–3200) G3: 2305 (1351–3221) P(G1–G3) = 0.050 Pad count, pad/d (range): G1: 0 (0–2) G2: 0 (0–2.5) G3: 1 (0–3) P(G1–G3) = 0.012 Urgency (subj) G1: 1.0 (0.0–12.3) G2: 6 (0.5–13) G3: 7.4 (3.9–13.4) P(G1–G3) < 0.001 Frequency (subj) G1: 7.8 (1.8–13.0) G2: 7.4 (2–14) G3: 10 (3.9–13.4) P(G1–G3) = 0.002 Nocturia (subj) G1: 0 (0–3.0) G2: 0 (0–2.5) G3: 1 (0–3.6) P(G1–G3) = 0.002 UI (subj) G1: 0.5 (0–2) G2: 0 (0–2) G3: 1 (0–2) P(G1–G3) = 0.413 P values before vs. after treatment Warning time, s (range): G1: 0.002 G2: 0.001 G3: 0.532 MVV, mL/void (range): G1: 0.018 G2: 0.004 G3: 0.979 Daily voided volume, mL (range): G1: 0.024 G2: 0.728 G3: 0.627 Pad per day (range): G1: 0.010 G2: 0.662 G3: 0.501 Urgency (subj): G1: <0.001 G2: <0.001 G3: 0.003 Frequency (subj): G1: <0.001 G2: <0.001 G3: 0.070 Nocturia (subj): G1: 0.001 G2: 0.394 G3: 0.176 UI (subj): G1: 0.814 G2: 0 083 G3: 0.854 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: − Pt selection criteria: + Loss to followup: ++ Drop-out rates: + Power calculation: + Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Wyman et al. 1998 Country and setting: US, Academic medical center Enrollment period: NR Funding: NIH Author industry relationship disclosures: NR | Design: RCT Intervention: 12-wk program of patient education, self-monitoring of voiding behaviors, compliance assessment, and positive-reinforcement techniques administered by trained RNs Groups: G1: Bladder Training (BT) G2: Pelvic muscle exercise (PME) G3: Combination therapy (CT) N at enrollment: Total: 204 G1: 68 G2: 69 G3: 67 N at follow-up, 3 mos: G1: 68 G2: 64 G3: 61 Age, mean ± SD: G1: 60 ± 10 G2: 62 ± 10 G3: 61 ± 9 Race/ethnicity, n (%): White: G1: 64 (94) G2: 62 (90) G3: 49 (91) Parity (vaginal births), mean ± SD: G1: 2.4 ± 1.7 G2: 2.6 ± 1.9 G3: 2.5 ± 1.7 P = 0.846 BMI, kg/m^2^ ± SD: G1: 28.4 ± 6.6 G2: 27.6 ± 5.8 G3: 26.8 ± 5.6 P = 0.288 | Inclusion criteria: • Age ≥ 45 • Community dwelling • Mentally intact • Able to toilet independently • Urine loss ≥1x/wk • Urodynamic evidence of GUI, DI or both Exclusion criteria: • Reversible cases of UI • Uncontrolled metabolic conditions • Residual urine volume after voiding > 100mL • UTI • Genitourinary fistula • Indwelling catheterization • Inability to correctly perform a pelvic muscle contraction on digital exam | Stress urinary incontinence, n (%): G1: 19 (28) G2: 35 (51) G3: 22 (33) P = 0.015 Urge urinary incontinence, n (%): G1: 8(12) G2: 6(9) G3: 10(15) Mixed urinary incontinence, n (%): G1: 41 (60) G2: 27 (39) G3: 35 (52) P = 0.044 Genuine stress incontinence by urodynamics, n (%): G1: 48 (71) G2: 48 (70) G3: 49 (73) Detrusor Instability by urodynamics, n (%): G1: 9 (13) G2: 10 (14) G3: 10 (15) DI + GSI by urodynamics, n (%): G1: 11 (16) G2: 11 (16) G3: 8 (12) Incontinence episodes/wk, mean ± SD: G1: 14.6 ± 11.2 G2: 16.8 ± 17.1 G3: 14.9 ± 13.8 Incontinence episodes/wk, DI ± GSI subgroup, mean ± SD: G1: 14.3 ± 10.3 G2: 20.7 ± 22.4 G3: 16.2 ± 13.7 Previous medical treatment for UI, n (%): G1: 14 (21) G2: 14 (21) G3: 16 (24) Previous surgical treatment for UI, n (%): G1: 15 (22) G2: 14 (21) G3: 22 (33) UDI QoL, mean ± SD: G1: 130.1 ± 48.8 G2: 119.7 ± 49.9 G3: 118.9 ± 46.9 UDI QoL, DI ± GSI subgroup, mean ± SD: G1: 143.2 ± 54.0 G2: 133.2 ± 59.6 G3: 115.4 ± 42.5 IIQ-R incontinence impact, mean ± SD: G1: 93.7 ± 74.2 G2: 75.6 ± 67.1 G3: 84.6 ± 67.8 IIQ-R incontinence impact, DI ± GSI subgroup, mean ± SD: G1: 118.5 ± 84.4 G2: 93.7 ± 90.3 G3: 84.0 ± 66.9 | Incontinence episodes/wk, immediately after treatment, mean ± SD: G1: 10.6 ± 16.3 G2: 9.6 ± 10.8 G3: 6.8 ± 10.7 P = 0.004 G1/G2: P = 0.796 G1/G3: P = 0.006 G2/G3: P = 0.003 Incontinence episodes/wk, immediately after treatment, DI ± GSI subgroup, mean ± SD: G1: 6.2 ± 9.1 G2: 11.9 ± 12.7 G3: 5.8 ± 9.5 Incontinence episodes, % reduction, immediately after treatment, n (%): 100%: G1: 12 (18) G2: 8 (13) G3: 19 (31) 75–99%: G1: 11 (16) G2: 8 (13) G3: 14 (23) 50–74%: G1: 12 (18) G2: 20 (31) G3: 10 (16) 0–49%: G1: 14 (21) G2: 13 (20) G3: 10 (16) None/worse: G1: 19 (28) G2: 15(23) G3: 8 (13) P = 0.050 Incontinence episodes/wk, 3 mos, mean ± SD: G1: 10.0 ± 12.0 G2: 9.4 ± 14.0 G3: 8.1 ± 12.4 P = 0.126 Incontinence episodes, % reduction, 3 mos, n (%): 100%: G1: 10 (16) G2: 13 (20) G3: 16 (27) 75–99%: G1: 9 (15) G2: 12 (22) G3: 13 (22) 50–74%: G1: 9 (15) G2: 9 (14) G3: 6 (10) 0–49%: G1: 15 (24) G2: 12 (18) G3: 15 (25) None/worse: G1: 19 (31) G2: 17 (26) G3: 10 (17) P = 0.587 UDI QoL, immediately after treatment, mean ± SD: G1: 95.5 ± 54.4 G2: 90.8 ± 52.0 G3: 64.4 ± 48.6 UDI QoL, immediately after treatment, DI ± GSI subgroup, mean ± SD: G1: 86.8 ± 54.8 G2: 114.8 ± 70.3 G3: 67.6 ± 48.5 P = 0.054 G1/G2: P = 0.37 G1/G3: P = 0.956 G2/G3: P = 0.038 UDI QoL, 3 months, mean ± SD: G1: 91.7 ± 55.0 G2: 85.0 ± 52.4 G3: 72.8 ± 50.4 P = 0.203 IIQ-R incontinence impact, immediately after treatment, mean ± SD: G1: 72.1 ± 75.2 G2: 56.8 ± 61.4 G3: 46.6 ± 65.3 IIQ-R incontinence impact, immediately after treatment, DI ± GSI subgroup, mean ± SD: G1: 81.2 ± 88.7 G2: 89.9 ± 79.4 G3: 31.8 ± 34.4 P = 0.0301 G1/G2: P = 0.357 G1/G3: P = 0.084 G2/G3: P = 0.009 IIQ-R incontinence impact, 3 months, mean ± SD: G1: 65.7 ± 80.2 G2: 59.3 ± 67.7 G3: 59.8 ± 83.9 P = 0.850 Patient perception of improvement, immediately after treatment, n (%): Much: G1: 25 (38) G2: 19 (30) G3: 32 (52) Some: G1: 18 (27) G2: 29 (46) G3: 23 (38) None: G1: 20 (30) G2: 13 (21) G3: 4 (7) Worse: G1: 3 (5) G2: 2 (3) G3: 2 (3) P = 0.011 Patient perception of improvement, 3 mos, n (%): Much: G1: 21 (35) G2: 24 (37) G3: 31 (53) Some: G1: 16 (27) G2: 21 (33) G3: 13 (22) None: G1: 19 (32) G2: 16 (25) G3: 12 (21) Worse: G1: 4 (7) G2: 3 (5) G3: 2 (4) P = 0.414 Patient satisfaction, immediately after treatment, n (%): Very satisfied: G1: 42 (64) G2: 46 (73) G3: 50 (82) Slightly satisfied: G1: 6 (9) G2: 10 (16) G3: 7 (11) Neither G1: 12 (21) G2: 6 (10) G3: 3 (5) Dissatisfied: G1: 4 (6) G2: 1 (2) G3: 1 (2) Patient satisfaction, 3 mos, n (%): Very satisfied: G1: 36 (60) G2: 42 (66) G3: 45 (78) Slightly satisfied: G1: 11 (18) G2: 11 (17) G3: 6 (10) Neither: G1: 8 (13) G2: 10 (16) G3: 5 (9) Dissatisfied: G1: 5 (8) G2: 1 (2) G3: 2 (3) P = 0.310 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: − Pt selection criteria: + Loss to follow up: ++ Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of follow up: + Measurement methods: + Measurement reliability: + Intervention description: +

Evidence Table 5 KQ2 Complementary and Alternative Therapies

Study Description | Study Design, Interventions, and Population | Inclusion/Exclusion Criteria | Symptom Characteristics | Outcomes | Quality Rating
Author: Emmons and Otto, 2005 Country and setting: US, Academic medical center Enrollment period: July 2000 to October 2002 Funding: Supported in part by grants from the Oregon Health Science Foundation and the Public Health Service Author industry relationship disclosures: NR | Design: RCT Intervention: Acupuncture Groups: G1: acupuncture with needles placed at sites intended to address overactive bladder with UUI; administered for 20 minutes during 4 weekly sessions G2: acupuncture with needles placed at sites intended to support relaxation; administered for 20 minutes during 4 weekly sessions N at enrollment: G1: 44 G2: 41 N at follow-up, 2–4 weeks: G1: 38 G2: 36 Women, %: 100 Age, mean ± SD: G1: 53 ± 13 G2: 51 ± 12 Race/ethnicity: Minority, % Parity, mean ± SD: G1: 1.8 ± 1.6 G2: 1.8 ± 1.6 Menopausal, n: G1: 21 G2: 20 | Inclusion criteria: • > 8 voids per day • Subjective urgency to void • Urge-associated incontinence ≥ twice during a 3 day period Exclusion criteria: • Current treatment with medications for OAB • Current treatment with acupuncture for other indications • Unable to walk • Unable to complete a 3-day voiding diary • Hematuria • Untreated UTI | UUI episodes/3 days, mean ± SD: G1: 16.2 ± 11.1 G2: 15.4 ± 10.2 P = 0.68 Incontinence episodes/3 days, mean ± SD: G1: 6.3 ± 7.3 G2: 8.9 ± 9.2 P = 0.09 Voids/3 days, mean ± SD: G1: 30.4 ± 7.8 G2: 32.7 ± 11.5 P = 0.40 Urinary distress inventory score, mean ± SD: G1: 8.4 ± 3.6 G2: 8.6 ± 5.5 P = 0.87 Incontinence impact questionnaire score, mean ± SD: G1: 8.9 ± 2.8 G2: 9.1 ± 2.6 P = 0.80 Functional bladder capacity (mL), mean ± SD: G1: 210 ± 88 G2: 199 ± 84 P = 0.50 Cystometric max capacity (mL), mean ± SD: G1: 371 ± 161 G2: 341 ± 126 P = 0.49 Cystometric volume (mL), first urge to void, mean ± SD: G1: 61 ±+/− 67 G2: 69 ±+/− 52 P = 0.84 Cystometric volume (mL), strong urge to void, mean ± SD: G1: 274 ± 144 G2: 241 ± 100 P = 0.26 Detrusor contractions during cystometry, n: G1: 7 G2: 11 P = 0.22 Incontinence surgery, n: G1: 8 G2: 6 | UUI episodes/3 days, mean ± SD (% change): G1: 11.4 ± 8.8 (30) G2: 15.0 ± 9.4 (3) G1/BL: P < 0.003 G1/G2: P = 0.016 Incontinence episodes/3 days, mean ± SD (% change): G1: 2.6 ± 3.1 (59) G2: 5.3 ± 5.9 (40) G1/BL: P < 0.003 G2/BL: P < 0.003 G1/G2: P = 0.71 Voids/3 days, mean ± SD (% change): G1: 26.2 ± 7.1 (14) G2: 33.1 ± 16.1 (4) G1/G2: P = 0.03 Urinary distress inventory score, mean ± SD (% change): G1: 3.6 ± 3.2 (57) G2: 5.8 ± 4.8 (32) G1/BL: P < 0.003 G2/BL: P < 0.003 G1/G2: P = 0.05 Incontinence impact questionnaire score, mean ± SD (% change): G1: 4.3 ± 2.7 (52) G2: 7.0 ± 3.5 (23) G1/BL: P < 0.003 G2/BL: P < 0.003 G1/G2: P = 0.004 Functional bladder capacity (mL), mean ± SD (% change): G1: 236 ± 99 (12) G2: 196 ± 85 (−2) G1/BL: P < 0.03 G1/G2: P = 0.01 Cystometric max capacity (mL), mean ± SD (% change): G1: 415 ± 205 (12) G2: 356 ± 193 (4) G1/G2: P = 0.049 Cystometric volume (mL), first urge to void, mean ± SD (% change): G1: 65 ± 80 (6) G2: 57 ± 75 (−19) G1/G2: P = 0.47 Cystometric volume (mL), strong urge to void, mean ± SD (% change): G1: 297 ± 167 (8) G2: 276 ± 156 (14) G1/BL: P < 0.03 G2/BL: P < 0.03 G1/G2: P = 0.75 Detrusor contractions during cystometry, n (% change): G1: 6 (3) G2: 10 (3) G1/G2: P = 0.98 Bleeding/bruising from the needles, %: 23 Minor discomfort with needle placement, %: 25 | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: ++ Power calculation: + Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Freeman and Baxby, 1982 Country and setting: UK, Academic medical center Enrollment period: NR Funding: NR Author industry relationship disclosures: NR | Design: Case series Intervention: 12 sessions of hypnotherapy Groups: NA N at enrollment: 63 N at follow-up: 44 Women, %: 100 Age, mean ± SD: 44.0 ± 15.6 Race/ethnicity: NR Follow-up: 3–14 months | Inclusion criteria: • Women • Detrusor instability by urodynamics • Normal cystoscopy • Normal neurological findings • No drugs that affect the detrusor Exclusion criteria: • Genuine stress incontinence • Flow rate < 15 ml/s • Voiding pressure > 70 cm H_2_O | Max cystometric capacity (mL), full study population, mean ± SD (range): 410.0 ± 13.3 (120–650) Max cystometric capacity (mL), urodynamic studies performed, mean ± SD: 378 ± 126 Height of unstable contraction (cm H_2_O), full study population, mean ± SD (range): 43.6 ± 22.1 (15–100) Height of unstable contraction (cm H_2_O), urodynamic studies performed, mean ± SD: 57.5 ± 23.3 Bladder volume (mL), first unstable contraction, full study population, mean ± SD (range): 318.0 ± 14.4 (50–650) Bladder volume (mL), first unstable contraction, uro-dynamic studies performed, mean ± SD: 245 ± 159 | Max cystometric capacity (mL), mean ± SD: 487 ± 117 Max cystometric capacity (mL), mean change ± SD: 92.3 ± 112.2 P < 0.001 Height of unstable contraction (cm H_2_O), mean ± SD: 39.0 ± 13.2 Height of unstable contraction difference (cm H_2_O), mean change ± SD: −18.5 ± 18.9 P < 0.01 Bladder volume (mL), first unstable contraction, mean ± SD: 337 ± 123 Bladder volume (mL), first unstable contraction, mean change ± SD: 92.2 ± 126 P < 0.02 Symptom free, n: 29 Considerably improved symptoms, n: 14 No change in symptoms, n: 7 Relapse, n: 1 year: 3 10 months: 1 8 months: 1 7 months: 1 2 months: 1 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: −, NR Baseline OAB status: NR Baseline characteristics: − Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Mak et al., 2007 Country and setting: Hong Kong, China, Gynecological hospital Enrollment period: January 2003 to March 2003 Funding: NR Author industry relationship disclosures: NR | Design: RCT Intervention: Foot reflexology vs nonspecific foot message Groups: G1: foot reflexology for 45 min G2: nonspecific foot massage for 45 min N at enrollment: G1: 60 G2: 60 N at follow-up: G1: 54 G2: 43 Women, %: 100 Age, mean ± SD: G1: 56.0 ± 13.4 G2: 56.4 ± 9.1 Race/ethnicity: NR Menopausal, n (%): G1: 33 (57.8) G2: 29 (67.4) P = 0.533 BMI, kg/m^2^, median (IQR): G1: 24.2 (21.6, 27.4) G2: 24.7 (21.8, 26.7) | Inclusion criteria: • Majority of leakage related to UI • Taking antimuscarinics with required 3 week washout Exclusion criteria: • SUI • UTI • Interstitial cystitis • Urinary tract obstruction • Organic disease of bladder or urethra • Pregnant • Breast-feeding • Pelvic, vaginal, or bladder surgery within 6 mos • Heart disease • Abnormal EKG | UUI episodes, median (IQR): G1: 0.5 (0, 2) G2: 1.0 (0, 2) P = 0.86 Urgency episodes, mean ± SD: G1: 2.22 ± 1.42 G2: 2.14 ± 1.12 P = 0.75 Voids/day, mean ± SD: G1: 11.3 ± 4.68 G2: 10.23 ± 3.53 P = 0.22 Daytime voids/day, mean ± SD: G1: 9.07 ± 4.59 G2: 8.09 ± 3.83 P = 0.26 Nocturia episodes, median (IQR): G1: 2 (1, 3) G2: 2 (1, 3) P = 0.94 Perceived severity, median (IQR): G1: 5.6 (3.9, 7.1) G2: 5.3 (3.1, 7.0) P = 0.18 KHQ, general health, mean score ± SD: G1: 56.0 ± 18.1 G2: 55.8 ± 17.1 P = 0.955 KHQ, incontinence impact, mean score ± SD: G1: 68.5 ± 30.6 G2: 69.7 ± 27.9 P = 0.836 KHQ, role limitations, mean score ± SD: G1: 39.8 ± 33.7 G2: 41.4 ± 33.8 P = 0.811 KHQ, physical limitations, mean score ± SD: G1: 37.3 ± 35.0 G2: 54.2 ± 78.6 P = 0.160 KHQ, social limitations, mean score ± SD: G1: 28.6 ± 30.2 G2: 35.1 ± 30.5 P = 0.294 KHQ, personal limitations, mean score ± SD: G1: 17.2 ± 29.9 G2: 24.4 ± 31.5 P = 0.358 KHQ, emotion, mean score ± SD: G1: 36.2 ± 33.5 G2: 44.1 ± 35.9 P = 0.262 KHQ, sleep/energy, mean score ± SD: G1: 36.1 ± 33.9 G2: 33.3 ± 29.9 P = 0.674 KHQ, severity measures, mean score ± SD: G1: 25.8 ± 21.1 G2: 25.5 ± 20.8 P = 0.959 Peak flow rate, ml/s ± SD: G1: 16.7 ± 9.75 G2: 18.5 ± 7.69 Max cystometric capacity, ml ± SD: G1: 378.1 ± 89.0 G2: 347.8 ± 94.0 P = 0.11 Duration of symptoms, median (IQR): G1: 5 (3, 9) G2: 6 (3, 10) Previous treatment for idiopathic detrusor overactivity, n (%): G1: 27 (47.3) G2: 22 (44.9) Previous continence surgery, n (%): G1: 5 (8.8) G2: 7 (16.3) | UUI episodes, median change (IQR): G1: 0 (−1, 0) G2: 0 (−1, 0) Urgency episodes, mean change ± SD: G1: 0.27 ± 0.94 G2: 0.48 ± 1.12 P = 0.32 Voids/day, mean change ± SD: G1: 2.18 ± 2.80 G2: 1.04 ± 2.92 P = 0.055 Daytime voids/day, mean change ± SD: G1: 1.90 ± 2.76 G2: 0.55 ± 3.21 P = 0.029 Nocturia episodes, median change (IQR): G1: −1 (−1, 0) G2: −1 (−1, 0)* P = 0.46 Frequency, change from > 8 to ≤ 8 after treatment, n (%): G1: 11 (20.3) G2: 7 (16.2) P = 0.482 Perceived severity, median change (IQR): G1: 1.5 (−0.65, 3.4) G2: 1.2 (−0.8, 3) P = 0.7 Perceived change of bladder symptoms, median (IQR): G1: 1.5 (0.5, 3) G2: 1.1 (0, 2) P = 0.172 KHQ, general health, mean change ± SD: G1: −5.55 ± 19.8 G2: −5.23 ± 19.3 P = 0.936 KHQ, incontinence impact, mean change ± SD: G1: −9.87 ± 32.7 G2: −14.72 ± 33.5 P = 0.477 KHQ, role limitations, mean change ± SD: G1: −3.08 ± 31.0 G2: −2.32 ± 28.5 P = 0.902 KHQ, physical limitations, mean change ± SD: G1: −1.54 ± 27.9 G2: −12.8 ± 71.9 P = 0.337 KHQ, social limitations, mean change ± SD: G1: −0.51 ± 29.1 G2: −6.97 ± 27.6 P = 0.267 KHQ, personal limitations, mean change ± SD: G1: 2.15 ± 29.1 G2: −10.1 ± 29.8 P = 0.116 KHQ, emotion, mean change ± SD: G1: 1.44 ± 30.4 G2: −10.0 ± 31.6 P = 0.074 KHQ, sleep/energy, mean change ± SD: G1: −5.8 ± 36.9 G2: −6.2 ± 36.2 P = 0.964 KHQ, severity measures, mean change ± SD: G1: −0.37 ± 8.8 G2: −1.86 ± 21.3 P = 0.720 Believed to have received intervention, %: G1: 88.9 G2: 67.4 P = 0.012 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: − Pt selection criteria: + Loss to followup: − Drop-out rates: + Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +

Evidence Table 6 KQ 3 Comparison of Treatments

Study Description | Study Design, Interventions, and Population | Inclusion/Exclusion Criteria | Symptom Characteristics | Outcomes | Quality Rating
Author: Abrams et al., 1998 Country and setting: UK, Ireland, Sweden, Academic medical center Enrollment period: July 1995 to July 1996 Funding: Pharmacia Upjohn Author industry relationship disclosures: NR | Design: RCT Intervention: Tolterodine vs. oxybutynin vs. placebo x 12 wks Groups: G1: Tolterodine 2mg bid (dose could be reduced to 1.5 mg b.i.d.) G2: Oxybutynin 5mg t.i.d. (dose could be reduced to 2.5 mg t.i.d.) G3: Placebo N at enrollment: G1: 118 G2: 118 G3: 57 N at follow-up: G1: 118 G2: 117 G3: 56 Women, n (%): G1: 91 (77.1) G2: 88 ( 74.5) G3: 43 (75.4) Age, mean (range): G1: 55 (19–80) G2: 58 (21–80) G3: 58 (26–78) | Inclusion criteria: • Age ≥ 18 • UDS confirmed bladder overactivity • ≥ 8 voids/day • ≥ 1 episode UUI/day Exclusion criteria: • SUI • Detrusor hyperreflexia • Hepatic, renal, hematological disorders • Symptomatic or recurrent UTI • BOO • Bladder retraining • Electrical stimulation therapy • Indwelling catheter • Intermittent catherization • Pregnant/nursing • Women without reliable BC | Incontinence episodes, n (%): G1: 93 (79) G2: 88 (75) G3: 40 (70) Incontinence episodes/day, mean (range): G1: 2.9 (0.1–24.0) G2: 2.6 (0.1–24.0) G3: 3.3 (0.1–23.5) Voids/day, mean (range): G1: 11.5 (6.3–37.0) G2: 10.7 (5.3–27.7) G3: 11.7 (6.9–34.4) ≥ 8 voids/day, n (%): G1: 112 (95) G2: 109 (92) G3: 53 (93) Voided volume (mL), mean (range): G1: 166 (55–426) G2: 176 (57–423) G3: 157 (59–276) Previous OAB therapy, n (%): G1: 61 (52) G2: 71 (60) G3: 43 (75) | Incontinence episodes/day, mean change ± SD: G1: −1.3 ± 3.2 G2: −1.7 ± 3.1 G3: −0.9 ± 1.5 G1/G3: P = 0.22 G2/G3: P = 0.023 Voids/day, mean change ± SD: G1: −2.7 ± 3.8 G2: −2.3 ± 2.7 G3: −1.6 ± 3.6 G1/G3: P = 0.002 G2/G3: P = 0.068 Voided volume (mL), mean change ± SD: G1: 38 ± 54 G2: 47 ± 58 G3: 6 ± 42 G1/G3: P < 0.001 G2/G3: P < 0.001 Subjective improvement in bladder symptoms, %: G1: 50 G2: 49 G3: 47 Dose reductions, n (%): G1: 9 (8) G2: 38 (32) G3: 1 (2) G2/G1: P < 0.001 G2/G3: P < 0.001 Dry mouth, n (%): G1: 59 (50) G2: 102 (86) G3: 12 (21) G1/G3: P < 0.001 G2/G1: P < 0.001 G2/G3: P < 0.001 Dyspepsia, n (%): G1: 11 (9) G2: 27 (23) G3: 3 (5) Nausea, n (%): G1: 4 (3) G2: 7 (6) G3: 6 (11) Upper respiratory infection, n (%): G1: 12 (10) G2: 3 (3) G3: 8 (14) Adverse events reported, N: G1: 302 G2: 412 G3: 117 Patients with ≥ 1 AE, n (%): G1: 105 (89) G2: 114 (97) G3: 46 (81) G2/G1: P = 0.023 G2/G3: P < 0.001 Discontinued due to AEs, n (%): G1: 10 (8) G2: 20 (17) G3: 1 (2) | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: + Masking: + Pt selection criteria: + Loss to followup: ++ Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Arruda et al., 2008 Country and setting: Brazil, community Enrollment period: August 2001 to September 2005 Funding: NR Author industry relationship disclosures: None | Design: RCT Intervention: Oxybutynin vs. functional electrostimulation vs. pelvic floor training Groups: G1: Oxybutynin 5 mg b.i.d. G2: Ambulatory stimulation applied vaginally G3: Pelvic floor exercises with a therapist and at home N Screened: 81 N at enrollment: G1: 22 G2: 21 G3: 21 N at follow-up: G1: 22 G2: 21 G3: 21 Age, range: 35–80 Race/ethnicity: NR Women, %: 100 Length of follow up: 12 weeks | Inclusion criteria: • Community-dwelling • Dx of OAB and DO • Capable of completing a bladder diary and performing a pelvic muscle floor contraction • For those with MUI, urge was predominant Exclusion criteria: • Hx of psychiatric or neurologic illness • Persistent UTI • Inability to comply with regular follow-up visits • Current pregnancy • Postvoid residual volume > 100 ml • Contraindications to anticholinergic therapy • Cardiac pacemaker • Type III SUI • Uncontrolled metabolic conditions or indwelling catheterization • Using medications including anticholinergic drugs, calcium antagonists, beta agonists, dopamine agonists, striated muscle relaxants or estrogens • Any uterine prolapse | UUI episodes/week, mean ± SD: G1: 13.8 ± 11.6 G2: 13.5 ± 15.6 G3: 16.4 ± 17.2 Nocturia episodes/week, mean ± SD: G1: 1.7 ± 1.5 G2: 1.9 ± 1.9 G3: 1.4 ± 1.2 Pads/day, mean ± SD: G1: 2.6 ± 2.7 G2: 2.3 ± 2.4 G3: 2.7 ± 1.5 Voids/day, mean ± SD: G1: 7.7 ± 2.6 G2: 8.6 ± 3.4 G3: 6.8 ± 2.2 Residual volume mean mL ± SD: G1: 3.2 ± 6.3 G2: 1.0 ± 2.6 G3: 1.8 ± 3.3 Volume, first desire to void, mean mL ± SD: G1: 117.7 ± 68.9 G2: 102.4 ± 51.1 G3: 86.7 ± 38.9 Maximal cystometric capacity, mean mL ± SD: G1: 410.4 ± 194.1 G2: 350.0 ± 212.9 G3: 424.0 ± 149.0 Involuntary detrusor contraction volume mean mL ± SD: G1: 189.5 ± 114.1 G2: 220.0 ± 127.2 G3: 239.3 ± 163.0 Involuntary detrusor contraction maximal pressure (mm H_2_0): G1: 39.4 ± 26.1 G2: 43.7 ± 22.9 G3: 34.2 ± 19.8 | UUI episodes/week, mean ± SD: G1: 7.0 ± 10.6 G2: 7.9 ± 13.7 G3: 7.8 ± 15.3 G1/BL: P = 0.007 G2/BL: P = 0.039 G3/BL: P = 0.035 Urgency resolved, n (%): G1: 14 (63.6) G2: 11 (52.4) G3: 12 (57.1) P = 0.754 Satisfied, n (%): G1: 17 (77.3) G2: 11 (52.4) G3: 16 (76.2) P = 0.142 Nocturia episodes/week, mean ± SD: G1: 0.9 ± 0.8 G2: 1.2 ± 1.3 G3: 1.0 ± 1.1 G1/BL: P = 0.003 G2/BL: P = 0.036 G3/BL: P = 0.086 Pads/day, mean ± SD: G1: 0.9 ± 1.5 G2: 0.9 ± 1.7 G3: 0.8 ± 1.3 G1/BL: P < 0.001 G2/BL: P = 0.004 G3/BL: P < 0.001 Voids/day, mean ± SD: G1: 6.4 ± 1.6 G2: 7.9 ± 2.3 G3: 7.1 ± 2.1 G1/BL: P = 0.014 G2/BL: P = 0.291 G3/BL: P = 0.441 Residual volume, mean mL ± SD: G1: 4.7 ± 9.4 G2: 1.1 ± 2.5 G3: 2.1 ± 3.5 G1/BL: P = 0.425 G2/BL: P = 0.760 G3/BL: P = 0.297 Volume first desire to void, mean mL ± SD: G1: 157.3 ± 63.8 G2: 123.8 ± 59.0 G3: 137.6 ± 76.7 G1/BL: P = 0.019 G2/BL: P = 0.091 G3/BL: P = 0.017 Maximal cystometric capacity mean mL ± SD: G1: 517.3 ± 191.7 G2: 436.6 ± 178.7 G3: 489.0 ± 141.3 G1/BL: P = 0.001 G2/BL: P = 0.017 G3/BL: P = 0.113 Involuntary detrusor contraction volume (mL): G1: 188.6 ± 183.2 G2: 73.3 ± 112.4 G3: 114.3 ± 154.2 G1/BL: P = 0.986 G2/BL: P = 0.001 G3/BL: P = 0.044 Involuntary detrusor contraction maximal pressure, mm H_2_0 ± SD: G1: 19.6 ± 20.9 G2: 22.4 ± 30.1 G3: 17.2 ± 25.5 G1/BL: P < 0.001 G2/BL: P = 0.002 G3/BL: P = 0.027 Normal urodynamic evaluation, n (%): G1: 8 (36.4) G2: 12 (57.1) G3: 11 (52.4) P = 0.358 Persistent improvement at 1 year: G1: 10/17 G2: 4/11 G3: 9/16 Dry mouth, n (%): G1: 16 (72.7) G2: 0 G3: 0 Difficulty voiding, n (%): G1: 2 (9.1) G2: 0 G3: 0 Dizziness, n (%): G1: 1 (4.5) G2: 0 G3: 0 Blurred vision, n (%): G1: 1 (4.5) G2: 0 G3: 0 Constipation, n (%): G1: 1 (4.5) G2: 0 G3: 0 Dry mouth, n (%): G1: 16 (72.7) G2: 0 G3: 0 Difficulty voiding, n (%): G1: 2 (9.1) G2: 0 G3: 0 Dizziness, n (%): G1: 1 (4.5) G2: 0 G3: 0 Blurred vision, n (%): G1: 1 (4.5) G2: 0 G3: 0 Constipation, n (%): G1: 1 (4.5) G2: 0 G3: 0 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: − Method and blinding: − Pt selection criteria: + Loss to followup: + Drop-out rates: − Power calculation: + Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: + Length of followup: + Measurement methods: − Measurement reliability: − Intervention description: +
Author: Burgio et al. 1998 Country and setting: US; academic health center outpatient geriatric medicine clinic Enrollment period: July 1989 to August 1995 Funding: National Institutes on Aging Author industry relationship disclosures: NR | Design: RCT, placebo controlled Computer-generated random numbers using a block size of 6, w/prior stratification by type and severity of incontinence Intervention: Biofeedback-assisted behavioral vs. drug treatment (oxybutynin chloride; possible range of doses 2.5 mg/d–5.0 mg t.i.d.) vs. placebo All patients had 4 visits over an 8-week period. Patients in G1 had biofeedback added to behavioral training in absence of 50% improvement by session 3. Groups: G1: Behavioral ± biofeedback G2: Pharmacologic G3: Placebo N at enrollment: 468 screened 271 not eligible 197 randomized G1: 65 G2: 67 G3: 65 N at follow-up: G1: 61 G2: 55 G3: 53 Women, %: 100 Age, yrs ± SD: G1: 67.3 ± 7.6 G2: 68.2 ± 7.5 G3: 67.6 ± 7.6 Race/ethnicity,: NR Parity mean ± SD: G1: 2.8 ± 2.0 G2: 2.1 ± 1.4 G3: 2.7 ± 1.8 | Inclusion criteria: • Community-dwelling women ≥ 55 years old • Ambulatory • ≥ 2 urge accidents per week by baseline bladder diary • Urge incontinence as predominant pattern • Urodynamic evidence of bladder dysfunction Exclusion criteria: • Continual leakage • Postvoid residual urine volume >200mL • Uterine prolapse past the introitus • Narrow-angle glaucoma • Unstable angina • Decompensated congestive heart failure • Hx of malignant arrhythmias • MMSE <20 (Dementia) | Duration of symptoms, mean yrs ± SD: G1: 9.4 ± 10.8 G2: 9.8 ± 11.9 G3: 12.7 ± 15.9 Restricted activity, (%): G1: 30.8 G2: 32.8 G3: 38.5 Urge UUI only, %: G1: 49.2 G2: 49.3 G3: 47.7 Accidents per week, mean n ± SD: G1: 15.8 ± 14.5 G2: 15.9 ± 14.1 G3: 15.4 ± 13.4 P=.98 Severity classification, %: Mild (<5 accidents/wk) G1: 18.5 G2: 17.9 G3: 18.5 Moderate (5–10 accidents/wk) G1: 29.2 G2: 29.9 G3: 27.7 Severe (>10 accidents/wk) G1: 52.3 G2: 52.2 G3: 53.8 Previous treatment with surgery, %: G1: 20.0 G2: 26.9 G3: 29.2 Previous treatment with medication, %: G1: 27.7 G2: 35.8 G3: 30.8 Using estrogen, %: G1: 32.3 G2: 38.8 G3: 35.4 Using diuretics, %: G1: 20.0 G2: 14.9 G3: 12.3 | Accidents per week, mean ± SD: G1: 2.8 ± 4.7 G2: 5.7 ± 9.8 G3: 8.2 ± 11.6 P=.005 Percent reduction, mean ± SD: G1: 80.7 ± 24.8 G2: 68.5 ± 37.2 G3: 39.4 ± 80.0 P<0.001 Percent reduction, range: G1: −0.9 – 100 G2: −85.7 – 100 G3: −400.0 – 100 Patient perceptions of progress in treatment Progress, %: Much better G1: 74.1 G2: 50.9 G3: 226.9 Better G1: 25.9 G2: 30.9 G3: 38.5 About the same G1: 0.0 G2: 16.4 G3: 28.8 Worse G1: 0.0 G2: 1.8 G3: 5.8 Estimate of % improvement, mean ± SD: G1: 81.6 ± 18.6 G2: 66.4 ± 35.4 G3: 45.1 ± 36.6 Having fewer accidents, %: G1: 100.0 G2: 87.3 G3: 67.3 Accidents are smaller, %: G1: 87.3 G2: 78.8 G3: 54.0 Able to wear less protection, %: G1: 76.0 G2: 56.0 G3: 334.1 Comfortable enough with treatment to continue indefinitely, %: G1: 96.5 G2: 54.7 G3: 43.1 Patient satisfaction with progress, %: Completely satisfied G1: 77.6 G2: 54.7 G3: 43.1 Somewhat satisfied G1: 22.4 G2: 40.0 G3: 34.0 Not at all satisfied G1: 0.0 G2: 10.9 G3: 38.0 Wish to receive another form of treatment, %: G1: 14.0 G2: 75.5 G3: 75.5 p<0.001 for all comparisons Adverse effects, %, p compared to placebo G3: Dry mouth G1: 34.9 G2: 96.9 G3: 54.8 p<0.001 Inability to void G1: 6.3 G2: 21.5 G3: 3.2 p=0.002 Constipation G1: 22.2 G2: 38.5 G3: 37.1 p=0.10 Blurred vision G1: 9.5 G2: 15.4 G3: 9.7 p=0.50 Confusion G1: 6.3 G2: 7.7 G3: 11.3 p=0.59 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Burgio et al. 2000 [See Burgio et al., 1998] Enrollment period: two weeks after completion of Burgio et al. 1998, #2440 Funding: National Institute on Aging, grants AG 08010 and K04 00431 Author industry relationship disclosures: NR | Design: Modified crossover of RCT Intervention: Participants whose treatment was not completely successful were given the opportunity to switch or use combined treatment; further reductions in incontinence were measured. Groups: [underlined: Treatment Changes:] G1: Previous oxybutynin to behavioral modification alone G2: Previous behavior alone to 2.5 mg oxybutynin t.i.d. + behavioral therapy G3: Previous oxybutynin alone to 2.5 mg oxybutynin t.i.d. + behavioral therapy G4: Placebo to behavioral G5: Placebo to oxybutynin N at enrollment G1: 19 G2: 8 G3: 27 G4: 34 G5: 10 N at follow-up: G1: 18 G2: 8 G3: 26 G4: NR G5: NR | Inclusion criteria: • Community-dwelling women at least age 55 • Ambulatory • At least 2 urge accidents per week by baseline bladder diary • Urge incontinence as predominant pattern • Urodynamic evidence of bladder dysfunction • not completely dry or satisfied with previous, 8-wk treatment Exclusion criteria: • Continual leakage • Postvoid residual urine volume >200mL • Uterine prolapse past the introitus • Narrow-angle glaucoma • Unstable angina • Decompensated congestive heart failure • Hx of malignant arrhythmias • MMSE <20 (Dementia) | % Reduction of incontinence after previous study (at baseline), mean: G1: 59.1 G2: 57.5 G3: 72.7 G4: 22.9 G5: 44.8 | Final % Reduction of incontinence mean, p: G1: 77.1, 0.109 G2: 88.5, 0.034 G3: 84.3, 0.001 G4: 63.9, .002 G5: 76.5, .012 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Burgio et al., 2001 [See Burgio et al,. 1998] Country and setting: US, University based Enrollment period: [See Burgio et al,. 1998] Funding: NIH Author industry relationship disclosures: NR | Design: RCT Intervention: Psychological distress associated with pharmacologic treatment vs. behavioral vs. placebo Groups: G1: Behavioral training with biofeedback, 4 visits G2: Oxybutynin 2.5 mg P.O. t.i.d., up to a max of 5 mg t.i.d. G3: Placebo N at enrollment: 197 women N treated: 169 N at follow-up: 155 (completed both pre and post-treatment psychological assessment) Age yrs, mean ± SD: 67.5 ± 7.2 Women, %: 100 Race/ethnicity, %: White: 97 African American: 3 | Inclusion criteria: • ≥ 55 yrs old • Ambulatory • UUI ≥2x/wk (2 wk bladder diary), persisting x 3 mo • Predominant UUI • UDS evidence of bladder dysfunction (DI or maximal capacity ≤350 mL) Exclusion criteria: • Contraindication to oxybutynin or behavioral treatment • Continual leakage • PVR > 200 mL • Uterine prolapse beyond the introitus • Decompensated CHF • Hx of malignant arrhythmias • Impaired mental status (MMSE <20) | SCL-90-R scores ± SD: Somatization G1: 56.0 (10.6) G2: 51.4 (10.8) G3: 52.4 (11.1) Obsessive-Compulsive: G1: 56.5 (10.7) G2: 56.6 (11.4) G3: 57.7 (10.0) Interpersonal Sensitivity G1: 53.8 (11.0) G2: 51.4 (11.9) G3: 50.4 (12.0) Depression G1: 54.7 (10.0) G2: 52.5 (9.7) G3: 51.0 (11.9) Anxiety G1: 48.7 (13.9) G2: 46.8 (12.0) G3: 47.2 (12.8) Hostility G1: 49.3 (10.7) G2: 45.9 (10.1) G3: 48.3 (10.4) Phobia G1: 47.5 (10.2) G2: 46.7 (10.3) G3: 45.7 (8.5) Paranoid Ideation G1: 48.6 (12.4) G2: 49.3 (11.1) G3: 46.1 (12.8) Psychoticism G1: 54.1 (10.7) G2: 52.1 (10.3) G3: 50.5 (11.2) Global Severity G1: 54.2 (11.1) G2: 52.5 (10.3) G3: 52.4 (11.2) 155 participants were compared to the 42 who did not complete intervention and psychological assessment, higher scores (greater distress) on 6 of 10 SCL-90-R scales (somatization, obsessive/compulsive, depression, hostility, paranoid ideation, global severity index), all p values <0.05 Normal range, score 0–63 >75% in normal range (including dropouts) on 9 of 10 scales Highest impairment rate: 33% scored abnormal for obsessive-compulsive | Reduction in incontinence: G1: 83.3% G2: 74.4% G3: 41.4% P<0.001 SCL-90-R scores ± SD: Somatization G1: 51.8 (11.4) G2: 51.2 (9.8) G3: 49.8 (13.0) Obsessive-Compulsive: G1: 53.8 (13.9) G2: 53.9 (10.9) G3: 55.4 (11.0) Interpersonal Sensitivity G1: 49.5 (12.0) G2: 48.9 (11.2) G3: 49.2 (11.3) Depression G1: 51.5 (11.5) G2: 50.6 (10.7) G3: 51.4 (11.2) Anxiety G1: 46.1 (14.6) G2: 44.5 (12.3) G3: 45.8 (12.9) Hostility G1: 44.9 (10.8) G2: 44.6 (10.5) G3: 47.3 (11.2) Phobia G1: 47.1 (11.2) G2: 45.0 (8.3) G3: 45.1 (8.5) Paranoid Ideation G1: 45.8 (10.9) G2: 47.2 (11.6) G3: 47.2 (12.0) Psychoticism G1: 49.2 (11.7) G2: 50.4 (9.7) G3: 49.6 (10.3) Global Severity G1: 50.8 (12.8) G2: 50.4 (10.0) G3: 51.4 (10.9) Correlations between Reduction of Incontinence and Changes in Psychological Symptoms Somatization G1: 0.28^*^ G2: −0.09 G3: 0.17 Obsessive-Compulsive G1: 0.01 G2: −0.14 G3: 0.02 Interpersonal Sensitivity G1: −0.09 G2: 0.04 G3: 0.13 Depression G1: −0.04 G2: 0.03 G3: 0.07 Anxiety G1: −0.10 G2: −0.01 G3: 0.34^*^ Hostility G1: −0.10 G2: 0.09 G3: 0.11 Phobic anxiety G1: −0.21 G2: −0.17 G3: 0.02 Paranoid Ideation G1: 0.14 G2: −0.04 G3: −0.06 Psychoticism G1: −0.01 G2: −0.01 G3: 0.13 Global Severity Index G1: 0.01 G2: 0.06 G3: 0.45^***^ ^*^p<0.05 ^***^P=0.001 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Burgio et al., 2008 Country and setting: US, Academic medical centers Enrollment period: July 2004 to January 2006 Funding: NIH Pfizer Author industry relationship disclosures: 20 of 29 Allergan (3) Alza (1) Astellas Pharma (7) Bionovo (1) Bristol-Meyers Squibb (1) Dynogen (1) Elan (1) Ethicon (2) GSK (4) Johnson & Johnson (3) Lilly (7) Medtronic (1) Merck (1) Novartis (6) Ortho-McNeil (3) Pfizer (>10) Procter & Gamble (3) Q-Med (1) Renessa (1) Sanofi (1) Solace (1) Watson (1) | Design: RCT Intervention: Pharmacologic vs. pharmacologic plus behavioral interventions for 10 wks (Stage 1), followed by no drug therapy (Stage 2) with assessments at 10 wks and 8 mos^*^ Groups: G1: tolterodine tartrate (ER capsules), 4 mg/d plus behavioral training: pelvic floor muscle control and exercises, behavioral strategies to diminish urgency, suppress bladder contractions and prevent both stress and urge incontinence; delayed voiding; fluid management; handout with hints G2: tolterodine tartrate (ER capsules), 4 mg/d N at enrollment: 4043 screened 2612 not eligible 870 declined 561 consented 254 excluded 307 randomized G1: 153 G2: 154 N at follow-up: G1: 153 Completed treatment: 107 Outcome known at 8 mos: 119 G2: 154 Completed treatment: 101 Outcome known at 8 mos: 118 Age, mean ± SD: G1: 55.8 ± 14.2 G2: 58.0 ± 13.5 Women, %: 100 Race/ethnicity, n (%): Hispanic: G1: 13 (9) G2: 17 (11) NH White: G1: 105 (69) G2: 85 (56) NH Black: G1: 22 (14) G2: 35 (23) Other: G1: 13 (9) G2: 15 (10) BMI, kg/m^2^ ± SD: G1: 33.2 ± 9.5 G2: 32.3 ± 7.6 | Inclusion criteria: • Women • Community-dwelling • UUI only, or urge-predominant incontinence • ≥ 7 episodes of incontinence in a 7-day bladder diary • Persistent incontinence for at least 3 mos • No antimuscarinics or other medications that could affect UI • No evidence of neurogenic etiology Exclusion criteria: • Age < 21 • Pregnant, or planning a pregnancy in next 8 mos, or not using birth control • < 6 mos postpartum or termination after 20 wks gestation • Unable to contract pelvic floor muscles • Behavioral therapy of > 2 mos in past 2 yrs • Continual leakage or always damp • Hypersensitive to study drug • Systemic disease that affects bladder function • Currently using catheter to empty bladder • Postvoid residual volume > 150mL • Treatment for prolapse with pessary < 3 mos • Incontinence, vaginal, bladder or prolapse surgery in the past 6 mos • Urethral diverticulum • Previous augmentation cystoplasty or artificial sphincter • Neuromodulation for pelvic indications • Using anticholinergic agents, cholinergic agonists, tricyclic antidepressants, or duloxetine in ≤ 4 wks • Using diuretics with dosage change past 3 mos • Uncontrolled medical problem • History of bladder or pelvic cancer or pelvic radiation therapy • Glaucoma • Gastric retention • Non-ambulatory • Participation in other intervention trial that might influence outcome | UUI, 7–13 episodes/week, n (%): G1: 2 (1.3) G2: 2 (1.3) UUI, ≥ 14 episodes/week, n (%): G1: 2 (1.3) G2: 4 (2.6) MUI, 7–13 episodes/week, n (%): G1: 46 (29.9) G2: 46 (30.1) MUI, ≥ 14 episodes/week, n (%): G1: 104 (67.5) G2: 101 (66.0) Adjusted incontinence episodes/week, mean: G1: 23.1 G2: 23.2 Previous non-surgical treatment for incontinence, n (%): G1: 19 (12) G2: 22 (14) | Success, n (%): G1: 43 (28) G2: 41 (27) Failure, n (%): G1: 75 (49) G2: 78 (51) 8 month success rate, lifetable analysis, % (95% CI): G1: 41 (32, 50) G2: 41 (33, 50) G1/G2: 0 (−12, 12) 8 mo success rate, complete cases, % (95% CI): G1: 36 (27, 45) G2: 34 (25, 43) G1/G2: 2 (−10, 14) 8 mo success rate, assuming missings were failures, % (95% CI): G1: 28 (21, 35) G2: 27 (20, 34) G1/G2: 1 (−9, 11) Adjusted incontinence episodes/week, after Stage 1, mean: G1: 2.7 G2: 4.7 Adjusted incontinence episodes/week, after Stage 1, mean change: G1: −20.4 G2: −18.5 G1/G2: −1.9 (−5.9, 2.0) Achieved 70% reduction in incontinence episodes, 10 wks (%): G1: 69 G2: 58 G1/G2: 11 (−0.3, 22.1) Totally dry, per bladder diary, 10 wks (%): G1: 21 G2: 17 Voids/day, mean change: G1: 0.5 G2: −0.4 G1/G2: 0.9 (0.3, 1.5) Symptom Distress Scores: G1/G2: P < 0.0001 Symptom Bother Scores (OAB-q), Stage 1, mean change: G1: −36.7 G2: −30.4 G1/G2: P < 0.0001 Symptom Bother Scores (OAB-q), Stage 2, mean change: G1: −30.9 G2: −20.4 G1/G2: P < 0.0001 Patient completely satisfied, Stage 1, %: G1: 53 G2: 40 G1/G2: 13 (1, 25) Patient completely satisfied, 8 months, %: G1: 33 G2: 20 G1/G2: 13 (2, 24) Patient better or much better, Stage 1, %: G1: 90 G2: 77 G1/G2: 13 (4, 22) Patient better or much better, 8 months, %: G1: 69 G2: 43 G1/G2: 26 (14, 38) Persistence in perceived improvement, 8 months, women with improvement at Stage 1: G1: 72 G2: 54 G1/G2: 17 (4, 30) Harms: G1: 3 participants 1: blurred vision, syncope, night sweats, stomach cramping and weakness 2: 2 episodes of small-bowel obstruction and an allergic reaction (pruritus and rash) 3: tachycardia during stage 2 G2: 3 participants 1: small bowel obstruction 2: peripheral edema 3: renal cell carcinoma diagnosis during stage 2 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: − Pt selection criteria: + Loss to followup: − Drop-out rates: ++ Power calculation: + Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Chancellor, Kianifard et al., 2008 Country and setting: US Enrollment period: May 2005 to February 2006 Funding: NR Author industry relationship disclosures: 6 of 7 Genaera (1) Novartis (6) | Design: Randomized open-label Intervention: Behavioral modification in addition to darifenacin (allowed to increase dose from darifenacin 7.5 mg to 15 mg daily after 2 weeks) Groups:* G1: Darifenacin G2: Darifenacin and behavioral modification N at enrollment: G1: 190 G2: 205 N at follow-up, 12 weeks: G1: 173 G2: 175 Age, mean ± SD: G1: 57.4 ± 13.1 G2: 58.4 ± 14.6 Race/ethnicity: White: G1: 90 G2: 88.3 Other (non-white): G1: 10 G2: 11.7 Women, %: G1: 90 G2: 88.3 | Inclusion criteria: •≥ 8 voids/day •≥ 2 UUI episodes/day •≥ 2 episodes of urgency/day Exclusion criteria: •Any drug with bladder effects for 2 weeks prior to study participation •Participation in any formal bladder-training program within 30 days of screening •Predominant SUI •Bladder or neurologic condition that could affect bladder function or in which use of anticholinergics was contra-indicated | UUI episodes/day, mean ± SD: G1: 2.78 ± 2.57 G2: 3.00 ± 2.56 UUI episodes/day, median: G1: 2.33 G2: 2.58 Mean UUI episodes/day, total population, n (%): 0 episodes: G1: 36 (19.1) G2: 29 (14.2) 1–6 episodes: G1: 138 (73.0) G2: 155 (76.0) 7–13 episodes: G1: 15 (7.9) G2: 20 (9.8) ≥14 episodes G1: 0 (0.0) G2: 0 (0.0) Mean UUI episodes/day, age ≥ 65, n (%) 0 episodes G1: 9 (17.0) G2: 8 (9.9) 1–6 episodes G1: 40 (75.5) G2: 63 (77.8) 7–13 episodes G1: 4 (7.5) G2: 10 (12.3) Urgency episodes/day, mean ± SD: G1: 10.88 ± 3.80 G2: 10.58 ± 4.00 Urgency episodes/day, median: G1: 10.67 G2: 10.33 Voids/day, mean ± SD: G1: 11.92 ± 3.03 G2: 11.75 ± 3.37 Voids/day, median: G1: 11.33 G2: 11.33 Nocturia episodes/day, mean ± SD: G1: 1.77 ± 1.43 G2: 1.87 ± 1.35 Nocturia episodes/day, median: G1: 1.67 G2: 1.67 Pads used/day, mean ± SD: G1: 1.12 ±1.93 G2: 0.99 ± 1.67 Pads used/day, median: G1: 0 G2: 0 | UUI episodes/day mean change ± SD: G1: −1.89 ± 2.29 G2: −2.10 ± 2.32 G1/G2: P = 0.268 UUI episodes/day median change (95% CI): G1: −1.33 (−2.00, −1.00) G2: −2.00 (−2.00, −1.33) Urgency episodes/day mean change ± SD: G1: −2.87 ± 3.59 G2: −2.68 ± 3.54 G1/G2: P = 0.882 Urgency episodes/day median change (95% CI): G1: −2.33 (−3.00, −1.67) G2: −2.67 (−3.00, −2.00) Voids/day, mean change ± SD: G1: −2.96 ± 2.91 G2: −2.82 ± 2.87 G1/G2: P = 0.681 Voids/day, median change (95% CI): G1: −2.67 (−3.33, −2.00) G2: −2.67 (−3.00, −2.33) Nocturia episodes/day, mean change ± SD: G1: −0.65 ± 1.26 G2: −0.67 ± 1.21 G1/G2: P = 0.315 Nocturia episodes/day, median change (95% CI): G1: −0.67 (−0.67, −0.33) G2: −0.67 (−0.67, −0.33) Pads used/day mean change ± SD: G1: −0.72 ±1.54 G2: −0.61 ± 1.28 G1/G2: P = 0.978 Pads used/day median change (95% CI): G1: 0 (0,0) G2: 0 (0,0) Side effects, %:** Constipation: 18.5 Dry mouth 25 UTI: 4.8 Headache: 3.8 Discontinued due to adverse event(s), n (%) G1: 6 (3.2) G2: 21 (10.25) Discontinued due to constipation, %: 2 Discontinued due to dry mouth, %: 1.8 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: − Pt selection criteria: + Loss to followup: + Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Chancellor, Zinner et al., 2008 Country and setting: USA, multicenter Enrollment period: NR Funding: Astellas Pharma US, Glaxo-SmithKline Author industry relationship disclosures: 12 of 12 Abbot (1) AEterna Zentaris (1) Akros (1) Allergan (3) American Medi-cal Systems (2) Amgen (1) Astellas (10) AstraZeneca (1) Bard (1) Bayer (1) Boehringer Ingelheim (3) Cephalon (1) Coloplast (1) Cook (1) CooperSurgical (1) Eli Lilly (2) Ferring GSK (6) Gynecare (1) Indevus (2) J&J (1) Mankind (1) Medtronic (1) Merck (1) Novartis (3) Novo Nordisk (1) Ortho-McNeil (1) Author industry relationship disclosures: Pfizer (7) Pharmacia (1) Pri Med (1) Reliant (1) Solvay (1) Sanofi-Aventis (1) Schering-Plough (1) Takeda (1) TAP (1) Watson (1) | Design: Prospective cohort, open label, flexible-dose, 14 day washout Intervention: Solifenacin 5–10 mg daily Groups: G1: Solifenacin 5–10 mg daily N at enrollment: G1: 440 N at follow-up (%): G1: 390 (88.4) Age, mean ± SD: G1: 61.4 ± 13.8 Race/ethnicity, n (%): White: G1: 392 (88.9) Women, N (%): G1: 389 (88.2) BMI, kg/m^2^ ± SD: G1: 30.1 ± 7.1 | Inclusion criteria: •Age ≥ 18 •OAB symptoms > 3 months •Treatment with tolterodine ER 4 mg, solifenacin, darifenacin, or trospium x ≥ 4 weeks •Desired change in therapy •≥ 3 mean UUI episodes/day Exclusion criteria: •Treatment < 4 weeks with tolterodine, solifenacin, darifenacin, or trospium •SUI •MUI with primary stress •UTI •Chronic bladder inflammation •Bladder cancer •Severe constipation •Elevated PVR •Neurological deficit •Renal/hepatic disease •Narrow angle glaucoma •Urinary retention •Gastric retention •Hypersensitivity to drugs •BOO •Women of childbearing age/lactation | Urgency episodes/day, mean change: G1: 6.9 ± 4.4 Incontinence episodes/day, mean ± SD: G1: 3.8 ± 3.6 Voids/day, mean ± SD: G1: 11.3 ± 3.8 Nocturia episodes/day, mean ± SD: G1: 1.9 ± 1.2 PPBC score, mean: G1: 4.2 OAB-q score, mean: Symptom bother: 57.3 Coping: 52.2 Concern: 51.3 Sleep: 50.6 Social Interaction: 77.7 Total score: 56.7 | Urgency episodes/day, mean change ± SD (95% CI): G1: −4.2 ± 4.2 (−4.6, −3.8) G1/BL: P < 0.001 Incontinence episodes/day, mean change ± SD (95% CI): G1: −2.6 ± 3.2 (−3.0, −2.3) G1/BL: P < 0.001 Voids/day, mean change ± SD (95% CI): G1: −2.3 ± 3.2 (−2.6, −2.0) G1/BL: P< 0.001 Nocturia episodes/day, mean change ± SD (95% CI): G1: −0.8 ± 1.0 (−0.9,−0.6) G1/BL: P < 0.001 PPBC score, mean change (95% CI): G1: −1.2 (−1.3, −1.0) G1/BL: P < 0.001 OAB-q score, mean: Symptom bother: 27.8 Coping: 80.1 Concern: 81.1 Sleep: 75.1 Social Interaction: 92.7 Total score: 81.9 G1/BL: P < 0.001 all domains and total score Dry Mouth, n (%): G1: 77 (17.5) Constipation, n (%): G1: 51 (11.6) Blurred vision, n (%): G1: 10 (2.3) UTI, n (%): G1: 19 (4.3) Headache, n (%): G1: 13 (2.9) URI, n (%): G1: 11 (2.5) | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: − Method and blinding: NA Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Chapple et al. 2003 Country and setting: 98 centers – United States, United Kingdom, Poland, Russia, New Zealand, Belgium, Netherlands Enrollment period: NR Funding: Yamanouchi Pharmaceutical Co., Ltd, Tokyo, Japan Author industry relationship disclosures: Not reported | Design: RCT, double-blind placebo controlled, with 2-wk placebo run-in period Intervention: tolterodine vs. solifenacin vs. placebo Groups: G1: tolterodine 2 mg bid G2: solifenacin 5 mg qd G3: solifenacin 10 mg qd G4: placebo qd N at enrollment: G1: 279 G2: 269 G3: 266 G4: 267 N at follow-up: G1: 250 G2: 266 G3: 264 G4: 253 Female, n (%) G1: 200 (80.0) G2: 188 (71.2) G3: 194 (72.9) G4: 193 (76.3) Age, yrs ± SD: G1: 56.9 +/−12.8 G2: 58.1± 13.4 G3: 57.2 ±13.4 G4: 57.8 ± 13.7 <65 years of age, n (%) G1: 169 (63.5) G2: 172 (65.2) G3: 172 (68.8) G4: 168 (66.4) ≥65 years of age, n (%) G1: 97 (36.5) G2: 92 (34.8) G3: 78 (31.2) G4: 85 (33.6) <75 years of age, n (%) G1: 236 (88.7) G2: 241 (91.3) G3: 233 (93.2) G4: 225 (88.9) ≥75 years of age, n (%) G1: 30 (11.3) G2: 23 (8.7) G3: 17 (16.8) G4: 28 (11.1) Weight, mean kg ± SD G1: 74.8 +/−14.8 G2: 74.6±14.3 G3: 75.5±14.2 G4: 72.6±14.4 Race, n (%) White G1: 261(98.1) G2: 260 (98.5) G3: 247(98.8) G4: 248 (98.0) Black G1: 2 (0.8) G2: 0 G3: 1 (0.4) G4: 1 (0.4) Asian G1: 2 (0.8) G2: 0 G3: 2(0.8) G4: 1 (0.4) Other G1: 1 (0.4) G2: 4 (1.5) G3: 0 G4: 3 (1.2) | Inclusion criteria: •≥ 18 years of age •symptoms of OAB (including urinary frequency with urgency and/or urge incontinence) for ≥3 months •≥8 voids per 24 hr •≥3 episodes urinary incontinence during 3-day diary period Exclusion criteria: •BOO •PVR >200 mL •stress predominant factor •neurological cause for detrusor overactivity •UTI or bladder stones •previous pelvic irradiation •malignant disease of pelvic organs •contraindication to antimuscarinic medication (including narrow-angle glaucoma, urinary or gastric retention) •non pharmacologic treatment for OAB 2 wks before study •diabetic neuropathy • use of drugs intended to treat incontinence • use of drugs with cholinergic or anticholinergic side-effects • participation in a clinical trial within 30 days • childbearing potential, pregnant or nursing or not using reliable contraceptive methods | UI only, n (%) G1: 142 (56.8) G2: 162 (61.4) G3: 172 (64.7) G4: 177(70.0) Mixed SI/UI, n (%) G1: 90 (36.0) G2: 81 (30.7) G3: 79 (29.7) G4: 59(23.3) No incontinence, n (%) G1: 18 (7.2) G2: 20 (7.6) G3: 15 (5.6) G4: 17 (6.7) Urgency episodes/24 h, mean ± SD G1: 5.77 ± 4.89 G2: 5.82 ± 4.45 G3: 5.45 ± 3.87 G4: 5.30 ± 3.92 UI/24 h, mean ± SD G1: 2.33 ± 2.50 G2: 2.14 ± 2.44 G3: 1.86 ± 1.54 G4: 2.02 ± 2.50 Incontinence episodes/24 h, mean ± SD: G1: 2.64 ± 2.55 G2: 2.59 ± 2.88 G3: 2.32 ± 1.94 G4: 2.71 ± 2.83 # Voids/24 h, mean ± SD: G1: 12.08± 3.86 G2: 12.32 ±3.95 G3: 12.08 ± 3.43 G4: 12.20 ± 4.11 Volume voided/void, mL, mean ± SD: G1: 149.6 ± 54.6 G2: 147.2 ±51.2 G3: 147.0 ± 50.3 G4: 143.8 ± 53.6 Time from start of symptoms, mean months (%) G1: 57.4 (60.5) G2: 72.6 (105.4) G3: 62.9 (82.5) G4: 61.0 (83.9) Prior drug therapy, n (%) G1: 93 (34.9) G2: 106 (40.1) G3: 77 (30.8) G4: 83 (32.8) Any non drug therapy, n (%) G1: 92 (34.6) G2: 92 (34.8) G3: 88 (35.2) G4: 76 (30.0) | Urgency episodes/24 h mean Δ from baseline: G1: −2.05 (3.58) G2: −2.85 (3.74) G3: −3.07 (3.90) G4: −1.41 (3.67) Urgency episodes/24 h Δ from baseline, %: G1: −38 G2: −55 G3: −52 G4: −33 Urgency episodes estimated difference vs. tolterodine (95%CI) G1: −0.791 (−14.34, −0.148) p<0.001 G2: −1.015 (−1.659, −0.370) p<0.001 G3: p=0.0511 UI/24 h mean Δ from baseline: G1: −0.91 (2.01) G2: −1.41 (1.74) G3: −1.36 (2.13) G4: −0.62 (1.96) UI/24 h Δ from baseline, %: G1: −58 G2: −65 G3: −63 G4: −40 UI estimated difference vs. tolterodine (95%CI) G1: −0.487 (−0.988, 0.014) p=0.002 G2: −0.436 (−0.921, 0.048) p=0.0028 G3: p=0.2390 Incontinence episodes/24 h mean Δ from baseline: G1: −1.42 (1.82) G2: −1.45 (2.24) G3: −1.14 (2.15) G4: −0.76 (2.26) Incontinence episodes/24 h Δ from baseline, %: G1: −59 G2: −47 G3: −59 G4: −29 Incontinence episodes estimated difference vs. tolterodine (95% CI) G1: −0.276 (−0.761, 0.208) p=0.008 G2: −0.316 (−0.786, 0.154) p=0.0038 G3: p=0.1122 Voids/24 h mean Δ from baseline: G1: −1.88 (3.00) G2: −2.19 (2.87) G3: −2.61 (3.24) G4: −1.20 (3.26) Voids/24 h Δ from baseline, %: G1: −15 G2: −20 G3: −17 G4: −18 Voids estimated difference vs. tolterodine (95%CI) G1: −0.312 (−0.844, 0.219) p=0.003 G2: −0.737 (−1.269, −0.204) p<0.001 G3: p=0.0145 Volume voided, mL mean Δ from baseline: G1: 24.4 (49.2) G2: 32.9 (47.7) G3: 39.2 (50.4) G4: 07.4 (36.3) Volume voided, mL Δ from baseline, %: G1: 20 G2: 25 G3: 29 G4: 9 Volume voided, mL estimated difference vs. tolterodine (95%CI) G1: 8.4 (0.496, 16.34) p,0.001 G2: 14.8 (6.855, 22.72) p<0.001 G3: p<0.001 Discontinued due to AEs, n (%): G1: 5 (1.9) G2: 9 (3.2) G3: 7 (2.6) G4: 10 (3.7) Dry mouth, n (%): G1: 49 (18.6) G2: 39 (14.0) G3: 57 (21.3) G4: 13 (4.9) Constipation, n (%): G1: 7 (2.6) G2: 20 (7.2) G2: 21 (7.8) G4: 5 (1.9) Blurred Vision, n (%): G1: 4 (1.5) G2: 10 (3.6) G3: 15 (5.6) G4: 7 (2.6) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: ++ Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Chapple et al., 2005 Chapple et al., 2007† Country and setting: European, Multicenter Enrollment period: May 2003 to October 2004 Funding: Yamanouchi (now Astellas) Author industry relationship disclosures: NR* 1 of 9† Astellas (1) Novartis (1) Pfizer (1) Schwartz (1) UCB (1) | Design: RCT Intervention: Solifenacin 5mg vs. tolterodine ER 4mg Groups: G1: solifenacin 5mg G2: tolterodine ER 4mg G1a: G1 who elected not to increase dose at 4 weeks G2a: G2 who elected not to increase dose at 4 weeks N at enrollment: G1: 578 G2: 599 N at follow-up: G1a: 297 G2a: 267 Age, mean: G1: 56.5 G2: 56.4 G1a: 56.5 G2a: 56.9 Race/ethnicity, %: White: G1: 99.3 G2: 99.5 G1a: 99.3 G2a: 99.3 Women, %: G1: 85.3 G2: 88.3 G1a: 87.5 G2a: 87.1 | Inclusion criteria: • Age ≥ 18 • OAB symptoms for ≥ 3 months • outpatient treatment • ≥ 8 voids/day • ≥ 1 incontinence episode/day or ≥ 1 urgency episode/day Exclusion criteria: NR | UUI episodes/day, mean ± SD:* G1: 2.31 ± 2.35 G2: 2.12 ± 2.14 UUI episodes/day, mean:† G1a: 1.97 G2a: 1.66 Urgency episodes/day, mean ± SD:* G1: 6.01 ± 4.66 G2: 5.84 ± 4.12 Urgency episodes/day, mean:† G1a: 5.67 G2a: 5.30 Incontinence episodes/day, mean ± SD:* G1: 2.77 ± 2.65 G2: 2.55 ± 2.37 Incontinence episodes/day, mean:† G1a: 2.32 G2a: 2.01 Voids/day, mean ± SD:* G1: 11.78 ± 3.58 G2: 11.66 ± 3.25 Voids/day, mean:† G1: 11.10 G2: 11.36 Nocturia, episodes/day, mean ± SD:* G1: 2.02 ± 1.33 G2: 1.92 ± 1.22 Nocturia, episodes/day, mean:† G1a: 1.83 G2a: 1.84 | UUI episodes/day, 4 wks, mean change:† G1: −1.22 G2: −0.91 P = NS UUI episodes/day, 12 wks, mean change:* G1: −1.42 G2: −0.83 P = 0.001 UUI episodes/day, 12 wks, mean change:† G1a: −1.46 G2a: −1.03 Urgency episodes/day, 4 wks, mean change:† G1: −1.98 G2: −1.67 P = NS Urgency episodes/day, 12 wks, mean change:* G1: −2.85 G2: −2.42 P = 0.035 Urgency episodes/day, 12 wks, mean change:† G1a: −3.08 G2a: −2.62 Incontinence episodes/day, 4 wks, mean change:† G1: −1.30 G2: −0.90 P = 0.0181 Incontinence episodes/day, 12 wks, mean change:* G1: −1.60 G2: −1.11 P = 0.006 Incontinence episodes/day, 12 wks, mean change:† G1a: −1.56 G2a: −1.23 Voids/day, 4 wks, mean change:† G1: −1.71 G2: −1.47 P = NS Voids/day, 12 wks, mean change:* G1: −2.45 G2: −2.24 P = 0.004 for non-inferiority Voids/day, 12 wks, mean change:† G1a: −2.47 G2a: −2.49 Nocturia, episodes/day, 4 wks, mean change:† G1: −0.51 G2: −0.44 P = NS Nocturia, episodes/day, 12 wks, mean change:* G1: −0.71 G2: −0.63 P = NS Nocturia episodes/day, 12 wks, mean change:† G1a: −0.72 G2a: −0.69 Perception of bladder condition, 4 wks, mean change:† G1: −0.96 G2: −0.88 P = NS Perception of bladder condition, 12 wks, mean change:* G1: −1.51 G2: −1.33 P < 0.0061 Perception of bladder condition, 12 wks, mean change:† G1a: −1.72 G2a: −1.62 Pad use, 4 wks, mean change:† G1: −1.21 G2: −0.80 P = 0.0089 Pad use, 12 wks, mean change:* G1: −1.72 G2: −1.19 P < 0.0023 Pad use, 12 wks, mean change:† G1a: −1.55 G2a: −1.40 Dry rate, 4 wks, mean % change:† G1: 39 G2: 34 P = NS Dry rate, 12 wks, mean % change:† G1a: 65.4 G2a: 58.3 Voided volume (mL), 4 wks, mean change:† G1: 28.51 G2: 24.29 P = NS Voided volume (mL), 12 wks, mean change:* G1: 38 G2: 31 P = 0.010 Voided volume (mL), 12 wks, mean change:† G1a: 39.95 G2a: 37.84 Dry mouth, mild, %:*† G1: 17.5 G2: 14.8 G1a: 6.5 G2a: 5.0 Dry mouth, moderate, %:*† G1: 10.8 G2: 7.7 G1a: 10.4 G2a: 7.0 Dry mouth, severe, %:*† G1: 1.7 G2: 1.5 G1a: 0.7 G2a: 2.1 Constipation, mild, %:*† G1: 3.2 G2: 1.3 G1a: 2.0 G2a: 1.0 Constipation, moderate, %:*† G1: 2.7 G2: 1.0 G1a: 1.7 G2a: 1.4 Constipation, severe, %:*† G1: 0.5 G2: 0.2 G1a: 0.3 G2a: 0.0 Blurred vision, mild, %:*† G1: 0.7 G2: 0.7 G1a: 0.3 G2a: 0.7 Blurred vision, moderate, %:*† G1: 0.0 G2: 1.0 G1a: 0.0 G2a: 1.7 Blurred vision, severe, %:*† G1: 0.0 G2: 0.0 G1a: 0.0 G2a: 0.0 | Quality: Overall quality score: good INTERNAL VALIDITY: good Randomization: + Masking: + Pt selection criteria: + Loss to followup: ++ Drop-out rates: ++ Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Chapple et al., 2008 Country and setting: European, multicenter (academic and private) Enrollment period: NR Funding: Pfizer, Schwarz BioSciences Author industry relationship disclosures: 4 of 5 Pfizer (4) | Design: Multicenter randomized placebo-controlled Intervention: Tolterodine 4 mg ER vs. fesoterodine 8 mg Groups: G1: Tolterodine ER 4mg G2: Fesoterodine 8mg G3: Placebo N at enrollment: G1: 290 G2: 287 G3: 283 Age, mean ± SD: Total: 57 ± 14 Race/ethnicity, %: White: Total: >95 Women, %: Total: 80 Follow-up: 12 weeks | Inclusion criteria: • Age ≥ 18 • OAB sx w/urinary urgency for ≥6 mos • ≥ 8 voids/day • ≥ 6 urgency episodes or ≥ 3 UUI episodes/day • At least moderate problems recorded via a Likert scale • Negative pregnancy test • Adequate contraception throughout trial Exclusion criteria: • LUT pathology: SI, bladder stones, interstitial cystitis, urothelial tumors • Grade III or higher pelvic prolapsed • Bladder-outlet obstruction • Polyuria (>3L/d) • Symptomatic or recurrent UTIs • PVR urine volume >100 mL • Antimuscarinic agent w/in 2 wks • Electrostimulation for bladder training in prior 4 wks • Active UTI • Underlying neurological disease • Clinically relevant cardiac arrhythmia • Unstable angina • QTcB interval > 500ms | Time since first diagnosis or onset of OAB (years), mean: Total: 8–9 Incontinent at BL, n: G1: 213 G2: 217 G3: 203 | KHQ severity score, mean change: G1: −12.6 G2: −14.0 G3: −9.0 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ severity score, patients incontinent at BL, mean change: G1: −14.9 G2: −15.8 G3: −10.8 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ emotions score, mean change: G1: −16.3 G2: −17.4 G3: −10.1 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ emotions score, patients incontinent at BL, mean change: G1: −17.3 G2: −18.6 G3: −11.3 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ role limitations score, mean change: G1: −22.1 G2: −21.7 G3: −11.8 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ role limitations score, patients incontinent at BL, mean change: G1: −23.2 G2: −23.7 G3: −12.4 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ physical limitations score, mean change: G1: −19.7 G2: −21.7 G3: −11.4 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ Physical limitations score, patients incontinent at BL, mean change: G1: −20.5 G2: −23.3 G3: −11.1 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ social limitations score, mean change: G1: −14.1 G2: −15.4 G3: −8.7 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ social limitations score, patients incontinent at BL, mean change: G1: −15.7 G2: −16.2 G3: −9.5 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ sleep/energy score, mean change: G1: −11.7G2: −13.6 G3: −9.6 G1/G3: P = NS G2/G3: P < 0.05 KHQ sleep/energy score, patients incontinent at BL, mean change: G1: −12.5 G2: −15.3 G3: −10.4 G1/G3: P = NS G2/G3: P < 0.05 KHQ personal relationship score, mean change: G1: −10.4 G2: −11.9 G3: −6.2 G1/G3: P = NS G2/G3: P < 0.05 KHQ personal relationship score, patients incontinent at BL, mean change: G1: −12.7 G2: −12.3 G3: −6.8 G1/G3: P < 0.05 G2/G3: P = NS KHQ incontinence impact score, mean change: G1: −23.3 G2: −24.6 G3: −16.1 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ incontinence impact score, patients incontinent at BL, mean change: G1: −23.8 G2: −26.5 G3: −17.7 G1/G3: P < 0.05 G2/G3: P < 0.05 KHQ general health score, mean change: G1: −4.3 G2: −4.0 G3: −3.8 G1/G3: P = NS G2/G3: P = NS KHQ general health score, patients incontinent at BL, mean change: G1: −4.3 G2: −4.5 G3: −5.5 G1/G3: P = NS G2/G3: P = NS ICIQ-SF total score, mean: G1: −3.95 G2: −4.41 G3: −2.55 G1/G3: P < 0.05 G2/G3: P < 0.05 ICIQ-SF total score, patients incontinent at BL, mean: G1: −4.56 G2: −5.29 G3: −3.12 G1/G3: P < 0.05 G2/G3: P < 0.05 Major improvement in severity of bladder-related problems, %: G1: 34 G2: 39 G3: 25 G1/G3: P = 0.01 G2/G3: P = 0.01 Dry mouth, n (%): G1: 49 (17) G2: 97 (34) G3: 20 (7) Constipation, n (%): G1: 8 (3) G2: 13 (5) G3: 4 (1) Nasopharyngitis, n (%): G1: 10 (3) G2: 5 (2) G3: 7 (3) Dry eye, n (%): G1: 1 (1) G2: 12 (4) G3: 0 (0) Nausea, n (%): G1: 6 (2) G2: 4 (1) G3: 1 (1) Fatigue, n (%): G1: 10 (3) G2: 1 (1) G3: 1 (1) Dry throat, n (%): G1: 3 (1) G2: 8 (3) G3: 0 (0) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Method and blinding: + Pt selection criteria: + Loss to followup: NR Drop-out rates: NR Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Colombo et al., 1995 Country and setting: Italy; Setting Enrollment period: May 1990 to March 1993 Funding: NR Author industry relationship disclosures: NR | Design: RCT, Computer generated random assignment Intervention: Oxybutynin vs. Bladder training for 6 weeks Groups: G1: Oxybutynin, 3 daily doses of 5 mg each for 6 weeks (dose reduced to half if substantial AEs) G2: Bladder training N at enrollment: G1: 42 G2: 39 N at 6 wk follow-up: G1: 38 G2: 37 N at 6 mo follow-up: G1: 28 G2: 27 Age, yrs ± SD: G1: 48 (31 – 65) G2: 49 (24 – 65) Race/ethnicity, mean ± SD: Black: NR Women, N (%): G1: 42 (100) G2: 39 (100) Postmenopausal n (%): G1: 16 (38) G2: 20 (51) | Inclusion criteria: • Socially embarrassing (severe) urinary urge incontinence • On cystometry: detrusor instability, or LCB, or sensory bladder Exclusion criteria: • Stable bladder at cystometry • Neurologic disease • Detrusor hyperreflexia • Age greater than 65 y • Coexisting genuine SUI • Genital prolapse • Postvoid residual volume >50mL • Previous gynecologic or urogynecologic surgery • Prior use of any drug to treat UUI • Urethral diverticula • Fistulas • Urinary tract neoplasia • Cystitis • Bladder stones • Previous pelvic radiotherapy | Detrusor instability, n (%): G1: 14 (37) G2: 13 (35) Low compliance bladder, n (%): G1: 9 (24) G2: 8 (22) Sensory bladder, n (%): G1: 15 (39) G2: 16 (43) Daily UUI episodes, range 9 – 17 Diurnal frequency, n (%): G1: 32 (84) G2: 29 (78) Nocturia, n (%): G1: 11 (29) G2: 18 (49) Volume at first desire (mL): G1: 120 ± 59 G2: 134 ± 61 Volume at very strong desire (mL): G1: 317 ± 92 G2: 332 ± 87 | Clinically cured overall, n (%): G1: 28 (74) G2: 27 (73) Cured among DI, (%): G1: 13 (93) G2: 8 (62) P=0.07 Cured among LCB: G1: 6 (67) G2: 6 (75) P=0.56 Cured among sensory bladder: G1: 9 (60) G2: 13 (81) P=0.18 Cured among 18 G1 patients requiring dosage halving: 12 (67%) Diurnal frequency resolved, n (%): G1: 18 (56) G2: 20 (69) Nocturia resolved n (%): G1: 3 (27) G2: 11 (61) Volume at first desire (mL), mean ± SD: G1: 179 ± 32 P=.0009 G2: 178 ± 49 P=.001 Volume at very strong desire (mL) mean ± SD: G1: 408 ± 76 P=.00001 G2: 403 ± 69 P=.0002 Patients still cured at 6 mos, n: G1: 16 G2: 26 Patients still cured at 6 mos among DI, n: G1: 8 G2: 8 Patients still cured at 6 mos among LCB, n: G1: 4 G2: 6 Patients still cured at 6 mos among sensory bladder, n: G1: 4 G2: 12 Treatment discontinued in 6 cases: G1: 4 (3 cases of severe dry mouth, 1 case of previously unknown glaucoma) G2: 2 (treatment was time consuming) Other adverse effects G1: 18 (47%) with AE requiring halving of dosage: -dry mouth (n=15) -constipation (n=6) -nausea (n=5) -dizziness (n=2) - decrease in visual acuity (n=1) - tachycardia (n=1) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: + Masking: − Pt selection criteria: + Loss to followup: ++ Drop-out rates: + Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: − Measurement methods: + Measurement reliability: − Intervention description: +
Author: Diokno et al. 1995 Country and setting: US; private clinic Enrollment period: January 1992 to December 1992 Funding: NR Author industry relationship disclosures: NR | Design: Cohorts with comparison; (Series of patients self selected into two groups) Intervention: Bladder training vs. anticholinergic or antispasmodic Groups: G1: Bladder training G2: oxybutynin 2.5–5.0 mg bid or t.i.d. N at enrollment: G1: 39 G2: 33 N at follow-up: G1: 26 G2: 28 Age, mean yrs (range): 64 (20–93) Race/ethnicity: NR Women, N (%): 72 (100) Parity mean ± SD: NR | Inclusion criteria: • Incontinent by AHCPR guidelines* • Incontinence persisted after treatment for transient incontinence Exclusion criteria: • Post-void residual of more than 150 mL | UUI, n (%): G1: 27 (49) G2: 28 (51) MUI with predominant urge, n (%): G1: 12 (71) G2: 5 (29) | Continent, n (%): G1: 1 (4) G2: 1 (4) Improved, n (%): G1: 22 (85) G2: 19 (68) No Change, n (%): G1: 3 (11) G2: 8 (28) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: − Loss to followup: − Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: poor Age: −, NR Baseline OAB status: NR Baseline characteristics: − Length of followup: ++ Measurement methods: − Measurement reliability: − Intervention description: +
Author: Diokno et al., 2003* Chu et al., 2005† Country and setting: US, Academic medical center Enrollment period: November 2000 to October 2001 Funding: ALZA Corporation, Ortho-McNeil Pharmaceuticals Author industry relationship disclosures: 5 of 7* ALZA (1) Indevus (1) Ortho-McNeil (4) Pharmacia (1) Watson (1) NR† | Design: RCT Intervention: Oxybutynin ER vs. Tolterodine ER 12 week treatment period Groups: G1: Oxybutynin ER 10 mg daily G2: Tolterodine ER 4mg daily N at enrollment: G1: 391 G2: 399 N at follow-up: G1: 339 G2: 357 Age, mean (range): G1: 60 (23–92) G2: 60 (18–85) Race/ethnicity, N (%): White: G1: 329 (84) G2: 342 (86) Black: G1: 32 (8) G2: 35 (9) Hispanic: G1: 27 (7) G2: 19 (5) Other: G1: 3 (1) G2: 3 (1) Women, N (%): G1: 391 (100) G2: 399 (100) | Inclusion criteria: • Age ≥ 18 • ≥ 21 episodes UUI/week • ≥ 10 voids/day • Urge > non-urge incontinence Exclusion criteria: • Treatable GU conditions causing incontinence • PVR > 150 mL by ultrasound × 2 • Risk of developing complete urinary retention • Medical problems worsened by anticholinergic effects • Hematuria • Uncontrolled narrow angle glaucoma • Obstructive uropathy • Reduced GI motility • Hypersensitivity to medications | UUI episodes/wk, mean ± SD: G1: 37.2 ± 15.2 G2: 36.9 ± 14.1 Total incontinence episodes/wk, mean ± SD: G1: 43.3 ± 19.3 G2: 42.6 ± 18.2 Voids/wk, mean ± SD: G1: 94.8 ± 25.4 G2: 96.2 ± 24.5 | UUI episodes/wk, mean: G1: 10.8 G2: 11.2 P = 0.28 Incontinence episodes/wk, mean: G1: 12.3 G2: 13.8 P = 0.08 Voids/wk, mean: G1: 66.4 G2: 71.1 P = 0.03 UUI episodes/wk, % reduction ± SD: G1: 72.0 ± 34.0 G2: 70.2 ± 33.2 P = 0.13 Incontinent episodes/wk, % reduction ± SD: G1: 72.8 ± 31.0 G2: 69.1 ± 34.9 P = 0.08 Voids/wk, % reduction ± SD: G1: 27.7 ± 19.7 G2: 24.9 ± 18.9 P = 0.05 Total dryness, %: G1: 23 G2: 16.8 P = 0.03 No UUI episodes, %: G1: 26.7 G2: 20.9 P = 0.06 Dry mouth, any degree, n (%): G1: 116 (29.7) G2: 89 (22.3) P = 0.02 Dry Mouth, mild, n (%): G1: 87 (22.3) G2: 69 (17.3) Dry mouth, moderate-severe, n (%): G1: 29 (7.4) G2: 20 (5.0) Constipation, n (%): G1: 25 (6.4) G2: 31 (7.8) Diarrhea, n (%): G1: 31 (7.9) G2: 25 (6.3) Headache, n (%): G1: 22 (5.6) G2: 24 (6.0) UTI, n (%): G1: 20 (5.1) G2: 13 (3.3) CNS AE, n (%):† G1: 35 (9.0) G2: 33 (8.3) Dizziness, n (%):† G1: 15 (3.8) G2: 10 (2.5) Dizziness, mild,** %:† G1: 1.8 G2: 1.5 Dizziness, moderate,** %:† G1: 0.8 G2: 0.3 Somnolence, n (%):† G1: 4 (1.0) G2: 9 (2.3) Somnolence, mild,** %:† G1: 0.5 G2: 1.5 Somnolence, moderate,** %:† G1: 0.3 G2: 0.5 Insomnia, n (%):† G1: 7 (1.8) G2: 3 (0.8) Insomnia, mild** %:† G1: 0.8 G2: 0 Insomnia, moderate,** %:† G1: 0.5 G2: 0 Depression, n (%):† G1: 5 (1.3) G2: 3 (0.8) Hypertonia, n (%):† G1: 2 (0.5) G2: 4 (1.0) Hypertonia, mild,** %:† G1: 0 G2: 0 Hypertonia, moderate,** %:† G1: 0.3 G2: 0 Anxiety, mild,** %:† G1: 0.5 G2: 0 Anxiety, moderate,** %:† G1: 0.3 G2: 0 Nervousness, mild,** %:† G1: 0 G2: 0 Nervousness, moderate,** %:† G1: 0.3 G2: 0 Tremor, mild,** %:† G1: 0.3 G2: 0.3 Tremor, moderate,** %:† G1: 0 G2: 0 Confusion, mild,** %:† G1: 0.3 G2: 0.3 Confusion, moderate,** %:† G1: 0 G2: 0 | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: − Masking: + Pt selection criteria: + Loss to followup: ++ Drop-out rates: ++ Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Giannitsas et al., 2004 Country and setting: Greece, Specialty treatment center Enrollment period: NR Funding: NR Author industry relationship disclosures: NR | Design: Randomized for which drug to receive first two-way crossover, table of random numbers Intervention: Oxybutynin 15 mg t.i.d. vs. Tolterodine 4mg bid; 6 weeks treatment with 3–4 weeks washout Groups: G1: Oxybutynin 15 mg t.id. G2: Tolterodine 4mg bid Stratified by UDS findings: a: high volume (> 250mL); low pressure (< 25cmH_2_O) b: high volume (≥ 250mL); high pressure (> 25cmH_2_O) C: low volume (< 250mL); low pressure (< 25cmH_2_O) d: low volume (< 250mL); high pressure (> 25cmH_2_O) N at enrollment: Total: 128 N at follow-up: Total: 107 Ga: 6 Gb: 25 Gc: 36 Gd: 40 Women, %: 100 Age, mean ± SD: Total: 56 ±16.3 Ga: 53 ± 17.2 Gb: 57 ± 16.2 Gc: 57 ± 16.3 Gd: 54 ± 16.6 Weight (kg), mean ± SD: Total: 63 ± 5.6 Ga: 63 ± 5.6 Gb: 70 ± 9.1 Gc: 67 ± 8.8 Gd: 69 ± 7.5 | Inclusion criteria: • Age ≥ 18 • DO on urodynamics Exclusion criteria: • Symptomatic or recurrent UTI • BOO • Neurologic disease • History of previous pelvic surgery • Narrow angle glaucoma • SUI • History of anticholinergic side effects • Interstitial cystitis • Child-bearing age without BC | Voids/day, mean ± SD: Total: 8.5 ± 2.63 Ga: 7.2 ± NR Gb: 8.0 ± 2.40 Gc: 8.3 ± 2.31 Gd: 9.3 ± 2.91 Volume (mL)/day, mean ± SD: Total: 1568.5 ± 398.64 Ga: 1756 ± NR Gb: 1594.6 ± 326.12 Gc: 1678.8 ± 402.15 Gd: 1420.5 ± 384.96 Voided volume (mL), mean ± SD: Total: 196.1 ± 60.19 Ga: 253 ± NR Gb: 213.5 ± 53.57 Gc: 209.8 ± 57.43 Gd: 163.4 ± 51.97 Bladder volume (mL), first desire void, mean ± SD: Total: 105.6 ± 39.38 Ga: 109 ± NR Gb: 128.0 ± 41.78 Gc: 94.3± 35.40 Gd: 101.1 ± 38.14 Bladder volume (mL), first contraction, mean ± SD: Total: 172 ± 98.4 Ga: 258 ± NR Gb: 303.3 ± 60.51 Gc: 111.9 ± 48.11 Gd: 124.4 ± 56.66 Pressure (cmH_2_0), first contraction, mean ± SD: Total: 34.8 ± 21.97 Ga: 17.4 ± NR Gb: 37.7 ± 14.03 Gc: 18.5 ± 4.60 Gd: 50.3 ± 25.14 Overactivity index, mean ± SD: Total: 36.8 ± 31.36 Ga: 15.3 ± NR Gb: 24.8 ± 19.66 Gc: 26.3 ± 16.14 Gd: 57.0 ± 38.85 Cystometric capacity (mL), mean ± SD: Total: 362.8 ± 119.10 Ga: 403 ± NR Gb: 410.0 ± 97.78 Gc: 357.6 ± 127.52 Gd: 331.4 ± 114.17 | Voids/day, mean ± SD: G1: 7.7 ± 1.87 G2: 7.6 ± 2.18 G1a: 6.1 ± NR G2a: 6.3 ± NR G1b: 7.3 ± 1.69 G2b: 7.0 ± 1.87 G1c: 7.5 ± 1.41 G2c: 7.2 ± 1.58 G1d: 8.3 ± 2.23 G2d: 8.4 ± 2.53 Volume (mL)/day, mean ± SD: G1: 1764.4 ± 333.03 G2: 1670.7 ± 338.6 G1a: 1862 ± NR G2a: 1720 ± NR G1b: 1715.6 ± 292.54 G2b: 1665.8 ± 251.19 G1c: 1847.9 ± 333.81 G2c: 1808.1 ± 317.59 G1d: 1694.7 ± 331.33 G2d: 1550.3 ± 373.65 Voided volume (mL), mean ± SD: G1: 239.9 ± 64.98 G2: 236.7 ± 63.03 G1a: 321 ± NR G2a: 286 ± NR G1b: 243.3 ± 59.56 G2b: 248.3 ± 53.91 G1c: 252.9 ± 55.75 G2c: 258.6 ± 60.63 G1d: 217.6 ± 67.07 G2d: 203.1 ± 55.43 Bladder volume (mL), first desire void, mean ± SD: G1: 129.0 ± 30.14 G2: 117.9 ± 27.62 G1a: 144 ± NR G2a: 140 ± NR G1b: 153.5 ± 25.72 G2b: 132.0 ± 31.01 G1c: 120.8 ± 25.07 G2c: 113.2 ± 23.16 G1d: 119.4 ± 29.43 G2d: 110.1 ± 26.15 G1/BL: P < 0.05 G2/BL: P < 0.05 Bladder volume (mL), first contraction, mean ± SD: G1: 212.9 ± 106.10 G2: 206.9 ± 103.56 G1a: 382 ± NR G2a: 364 ± NR G1b: 355.28 ± 74.79 G1c: 142.4 ± 43.51 G2c: 144.6 ± 48.43 G1d: 173.3 ± 57.37 G2d: 162.7 ± 53.87 G1d/BL: P < 0.01 G2d/BL: P < 0.01 Pressure (cmH_2_0), first contraction, mean ± SD: G1: 30.9 ± 22.63 G2: 30.9 ± 19.01 G1a: 14.0 ± NR G2a: 17.4 ± NR G1b: 35.6 ± 12.86 G2b: 29.6 ± 13.56 G1c: 17.2 ± 6.80 G2c: 17.9 ± 6.69 G1d: 42.9 ± 28.91 G2d: 44.1 ± 20.75 Overactivity index, mean ± SD: G1: 24.4 ± 22.61 G2: 24.7 ± 23.46 G1a: 7.0 ± NR G2a: 9.5 ± NR G1b: 14.1 ± 12.09 G2b: 14.1 ± 12.71 G1c: 18.3 ± 15.89 G2c: 16.9 ± 16.84 G1d: 38.9 ± 26.50 G2d: 40.7 ± 26.58 Cystometric capacity (mL), mean ± SD: G1: 419.3 ± 120.86 G2: 415.63 ± 114.06 G1a: 465 ± NR G2a: 453 ± NR G1b: 449.6 ± 106.23 G2b: 459.4 ± 101.17 G1c: 409.9 ± 130.22 G2c: 411.05 ± 132.49 G1d: 401.8 ± 118.34 G2d: 386.7 ± 96.53 Dry mouth, n (%): G1: 52 (40.6) G2: 20 (15.6) Constipation, n (%): G1: 11 (10.3) G2: 3 (2.8) Discontinued due to AEs, n: Dry mouth: 12 Palpitations: 1 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: + Masking: NA Pt selection criteria: + Loss to followup: ++ Drop-out rates: − Power calculation: − Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Goode et al., 2002 Country and setting: US; academic health center outpatient geriatric medicine clinic Enrollment period: July 1989 to August 1995 Funding: National Institutes on Aging Author industry relationship disclosures: NR | Design: RCT, placebo controlled Computer-generated random numbers using a block size of 6, w/prior stratification by type and severity of incontinence Intervention: Biofeedback-assisted behavioral vs. drug treatment (oxybutynin chloride; possible range of doses 2.5 mg/d-5.0 mg t.i.d.) vs. placebo All patients had 4 visits over an 8-week period. Patients in G1 had biofeedback added to behavioral training in absence of 50% improvement by session 3. Groups: G1: Behavioral ± biofeedback G2: Pharmacologic G3: Placebo N at enrollment: 468 screened 271 not eligible 197 randomized 105 had pre and post treatment urodynamics G1: 33 G2: 35 G3: 37 Age, yrs ± SD: G1: 65.3 ± 4.5 G2: 67.9 ± 7.9 G3: 67.6 ± 7.7 Race/ethnicity, %: Black: 2 White: 98 Women: 100% Parity mean ± SD: G1: 3.1 ± 1.7 G2: 2.1 ± 1.3 G3: 2.3 ± 1.5 | Inclusion criteria: • Community-dwelling women at least age 55 • Ambulatory • At least 2 urge accidents per week by baseline bladder diary • Urge incontinence as predominant pattern • Urodynamic evidence of bladder dysfunction Exclusion criteria: • Continual leakage • Postvoid residual urine volume >200mL • Uterine prolapse past the introitus • Narrow-angle glaucoma • Unstable angina • Decompensated congestive heart failure • Hx of malignant arrhythmias • MMSE <20 (Dementia) | Voids per day, mean n ± SD: G1: 10.0 G2: 10.9 G3: 10.0 [underlined: Cystometry at baseline, mL] First desire to void G1: 97.1 ± 50.7 G2: 101.1 ± 62.1 G3: 124.6 ± 73.7 Strong desire to void G1: 188.5 ± 93.1 G2: 212.1 ± 86.7 G3: 222.3 ± 87.0 Bladder capacity G1: 288.3 ± 117.0 G2: 308.7 ± 93.7 G3: 328.9 ± 107.6 | Voids per day, mean n ± SD: G1: 8.2 G2: 8.8 G3: 9.7 DI on UDS, n (%) +Baseline DI/+DI post-treatment G1: 7 (21.2) G2: 1 (2.9) G3: 5 (13.5) DI on UDS, n (%) +Baseline DI/−DI post-treatment G1: 1 (3.0) G2: 7 (20.0) G3: 7 (18.9) DI on UDS, n (%) −Baseline DI/+DI post-treatment G1: 3 (9.1) G2: 3 (8.6) G3: 3 (8.1) DI on UDS, n (%) −Baseline DI/−DI post-treatment G1: 22 (66.7) G2: 24 (68.6) G3: 22 (59.5) Cystometry post-treatment, mL First desire to void G1: 115.9 ± 64.9 G2: 145.6 ± 74.0 G3: 133.5 ± 59.6 Strong desire to void G1: 228.9 ± 106.4 G2: 282.0 ± 93.2 G3: 230.1 ± 78.8 Bladder capacity G1: 305.6 ± 117.9 G2: 377.6 ± 92.1 G3: 323.0 ± 109.0 Cystometry, change in mean volume by group First desire to void G1: 18.8 G2: 44.4 G3: 8.9 P= 0.149 Strong desire to void G1: 40.5 G2: 69.9 G3: 7.8 P= 0.018 Bladder capacity G1: 17.3 G2: 68.9 G3: −6.0 P= 0.000 [underlined: Standardized Estimates of Direct and Mediated Effects of Treatment] G1 v G3 Total effect: 0.28* Direct effect: 0.23 Mediated Effect: 0.05 G2vG3 Total Effect: 0.34* Direct Effect: 0.30* Mediated Effect: 0.04 *P<0.01 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Halaska et al., 2003 Country and setting: Europe and Asia, Academic medical center Enrollment period: May 1996 to May 1999 Funding: NR Author industry relationship disclosures: NR | Design: Randomized controlled double blind crossover Intervention: Trospium vs. Oxybutynin Groups: G1: Trospium 20 mg bid G2: Oxybutynin 5mg bid N at enrollment: G1: 268 G2: 90 N at follow-up: G1: 200 G2: 66 Women, n (%): G1: 228 (85) G2: 78 (87) Age, mean (range): G1: 54.2 (19, 89) G2: 52.2 (19, 85) Weight (kg), mean (range): G1: 72.3 (50–120) G2: 70.4 (50–90) Height (cm), mean (range): G1: 164.8 (144–185) G2: 165.5 (145–183) Smokers, n (%): G1: 38 (14) G2: 10 (11) Previous illness, n (%): G1: 184 (69) G2: 66 (73) Previous medication, n (%): G1: 101 (38) G2: 46 (51) | Inclusion criteria: • Age ≥ 18 yrs • Urge syndrome • Urge incontinence • UUI as one component of MUI • UUI due to neurologic condition (detrusor hyperreflexia) Exclusion criteria: • Absolute tachycardia • Closed angle glaucoma • Myasthenia gravis • Arteriosclerosis of cerebral vessels • SUI • Heart or renal failure • Frequency from diuretics • BOO • Acute UTI • Hiatus hernia with reflux esophagitis • Stenosis of GI tract • Megacolon • Colonic ulceration • Allergy to study medications • Anticholinergics, TCAs, alpha blockers, beta sympathomimetics ≤ 7 days • Urological or gynecologic surgery ≤ 3 mos • Pregnant or lactating • In another study | Urgency episodes/day, mean: G1: 10.2 G2: 11.0 Incontinence episodes/day, mean: G1: 1.5 G2: 2.1 Voids/day, mean: G1: 11.4 G2: 12.5 Max cystometric capacity (mL), mean: G1: 205 G2: 205 | Urgency episodes/day, mean: G1: 6.7 G2: 7.4 Incontinence episodes/day, mean: G1: 0.5 G2: 1.1 Voids/day, mean: G1: 7.9 G2: 8.3 Max cystometric capacity (mL), 26 wks, mean change: G1: 92.0 G2: 117.0 G1/BL: P ≤ 0.001 G2/BL: P ≤ 0.001 Max cystometric capacity (mL), 52 wks, mean change: G1: 115.0 G2: 119.4 G1/BL: P ≤ 0.001 G2/BL: P ≤ 0.001 Bladder volume (mL), first contraction, 26 wks, mean change: G1: 63.5 G2: 61.2 Bladder volume (mL), first contraction, 52 wks, mean change: G1: 46.1 G2: 36.7 Bladder volume (mL), first sensation, 26 wks, mean change: G1: 73.6 G2: 76.93 Bladder volume (mL), first sensation, 26 wks, mean change: G1: 78.6 G2: 70.2 Abnormal EKG, n (%): G1: 4 (0.1) G2: 2 (0.2) Any adverse event, n (%): G1: 10 (3.7) G2: 6 (6.7) Poor efficacy, n (%): G1: 8 (3) G2: 2 (2.2) Poor compliance, n (%): G1: 15 (15.6) G2: 6 (6.7) Abdominal pain, n (%): G1: 5 (2) G2: 0 (0) Constipation, n (%): G1: 18 (7) G2: 4 (4) Diarrhea, n (%): G1: 2 (1) G2: 2 (2) Dyspepsia, n (%): G1: 13 (5) G2: 3 (3) Dysphagia, n (%): G1: 9 (3) G2: 3 (3) Dry mouth, n (%): G1: 87 (33) G2: 45 (50) P < 0.001 Nausea, n (%): G1: 6 (2) G2: 2 (2) UTI, n (%): G1: 33 (12) G2: 10 (11) Headache, n (%): G1: 11 (4) G2: 8 (9) Visual disturbances, n (%): G1: 9 (3) G2: 5 (6) Virus infection, n (%): G1: 9 (3) G2: 4 (4) Abnormal EKG, n (%): G1: 4 (0.1) G2: 2 (0.2) Sleeplessness, n (%): G1: 10 (4) G2: 2 (2) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: − Pt selection criteria: + Loss to followup: ++ Drop-out rates: ++ Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Herschorn et al., 2004 Country and setting: Canada; Family medicine and urology clinics Enrollment period: June 2000 to December 2001 Funding: Pharmacia Pfizer Canada Author industry relationship disclosures: NR | Design: RCT Intervention: Health education with tolterodine vs. tolterodine alone Groups: G1: Health education with tolterodine G2: tolterodine alone N at enrollment: G1: 39 G2: 45 N at follow-up, 5 weeks: G1: 37 G2: 40 N at follow-up, 10 weeks: G1: 35 G2: 32 N at follow-up, 16 weeks: G1: 34 G2: 31 Age, yrs ± SD: G1: 65.7 ± 14.5 G2: 63.1 ± 15.7 Race/ethnicity: NR Women, %: G1: 92.3 G2: 84.4 Parity: NR | Inclusion criteria: • Age ≥ 50 • Symptoms of OAB^ • Attend investigators’ practice • Normal cognitive function • Able to read English Exclusion criteria: • Enrollment in another clinical trial • Interstitial cystitis • UTI • Already taking tolterodine | Duration of OAB, yrs ± SD: G1: 8.7 ± 11.0 G2: 8.7 ± 10.8 Mild bladder problems, n (%): G1: 13 (33.3) G2: 13 (28.9) Moderate bladder problems, n (%): G1: 19 (48.7) G2: 28 (62.2) Severe bladder problems, n (%): G1: 7 (18.0) G2: 4 (8.9) Obtained prescription, n (%): G1: 38 (97.4) G2: 37 (82.2) P < 0.05 Intends to fill prescription, (%): G1: 0 (0) G2: 6 (7.5) | Change in incontinence episodes/wk, mean ± SD: G1: −7.72 ± 21.16 G2: −10.24 ± 19.56† Change in voids/d, mean ± SD: G1: −1.82 ± 3.41 G2: −2.18 ± 4.89 P = NR Change in nocturnal voids, mean ± SD: G1: −0.44 ± 1.13† G2: −0.07 ± 0.91 No change in bladder problem severity, n (%): G1: 14 (42.4) G2: 20 (66.7) Improved bladder problem severity, n (%): G1: 15 (45.4)† G2: 6 (20) Worsened bladder problem severity, n (%): G1: 4 (12.1) G2: 4 (13.3) Compliance, 10 weeks, %: G1: 41 G2: 38 P > 0.05 Compliance, 16 weeks, %: G1: 39 G2: 31 P > 0.05 Continued or started non-drug OAB treatment, 16 weeks, %: G1: 82 G2: 53 P > 0.05 Stopped non-drug OAB treatments, %: G1: 12.8 G2: 28.9 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: − Masking: − Pt selection criteria: + Loss to followup: − Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: NR Baseline characteristics: − Length of followup: ++ Measurement methods: + Measurement reliability: − Intervention description: +
Author: Jarvis et al., 1981 Country and setting: UK, Academic medical center Enrollment period: NR Funding: NR Author industry relationship disclosures: NR | Design: RCT Intervention: Inpatient bladder drill vs. outpatient drug therapy Groups: G1: inpatient bladder drill G2: flavoxate hydrochloride 200 mg tds and imipramine 25 mg tds × 4 wks N at enrollment: G1: 25 G2: 25 N at follow-up: G1: 25 G2: 25 Women, %: 100 Age, mean ± SD (range): G1: 47 ± 15.4 (17-78) G2: 46 ± 12.8 (17-65) | Inclusion criteria: • Women • UDS-diagnosed detrusor instability Exclusion criteria: • DM • Neurological abnormalities • UTIs • Taking a drug suspected of affecting lower urinary tract function • Genuine stress incontinence | UUI, n: G1: 25 G2: 25 SUI, n: G1: 19 G2: 17 Urgency, n: G1: 25 G2: 25 Frequency, n: G1: 25 G2: 25 Nocturia, n: G1: 21 G2: 19 Duration of symptoms (years), mean ± SD (range): G1: 4.3 ± 2.7 (1-15) G2: 5.4 ± 3.2 (1-20) Bladder volume (mL), first sensation, mean: G1: 87 G2: 79 Max cystometric capacity (mL), mean: G1: 381 G2: 353 | UUI, n: G1: 4 G2: 11 SUI, n: G1: 1 G2: 9 Urgency, n: G1: 4 G2: 11 Frequency, n: G1: 6 G2: 12 Nocturia, n: G1: 4 G2: 13 Continent, n (%): G1: 21 (84) G2: 14 (56) P < 0.05 Symptom-free, n (%): G1: 19 (76) G2: 12 (48) P < 0.05 Bladder volume (mL), first sensation, mean: G1: 152 G2: 140 Max cystometric capacity (mL), mean: G1: 470 G2: 446 Adverse events, drug therapy, n:* Dizziness: 8 Headache: 6 Dry mouth: 6 Nausea: 4 Drowsiness: 2 Vomiting: 1 Discontinued due to AEs, n: Dizziness: 1 Headache: 1 Vomiting: 1 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: − Masking: − Pt selection criteria: + Loss to follow up: ++ Drop-out rates: − Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of follow up: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Lauti et al., 2008 Country and setting: New Zealand, Academic Enrollment period: February 2003 to July 2003 Funding: University of Otago Author industry relationship disclosures: None | Design: RCT pilot study, unmasked Intervention: Oxybutynin vs. bladder retraining vs. combination therapy Groups: G1: Oxybutynin 2.5 mg/day (daily dose could be increased by 2.5 mg every 5 days to a maximum of 15 mg/day) G2: Bladder retraining G3: Combination therapy N screened: 120 N at enrollment: G1: 21 G2: 16 G3: 19 N at 3 month follow-up: G1: 18 G2: 16 G3: 12 N at 12 month follow-up: G1: 16 G2: 14 G3: 12 Age, mean ± SD: G1: 53.8 ± 14.8 G2: 63.9 ± 17.2 G3: 47.6 ± 16.3 Race/ethnicity: NR Women, %: Total: 100 Parous, %: G1: 81 G2: 62.5 G3: 73.7 | Inclusion criteria: • Age > 18 • Predominant UUI Exclusion criteria: • Predominant SUI • Contraindications to anticholinergic drugs • Current UTI • Neurological disease • Psychiatric disorder • Untreated co-existing pelvic organ prolapse below the hymenal ring • Obstructed voiding • Functional-reversible cause of incontinence • Inability to toilet independently • Limited fluency of written/spoken English • Current or recent use of any of the trial interventions | Urgency episodes/day, mean ± SD: G1: 3.8 ± 2.7 G2: 3.1 ± 2.2 G3: 3.5 ± 2.0 Incontinence episodes/day, mean ± SD: G1: 2.2 ± 1.5 G2: 1.0 ± 1.1 G3: 1.8 ± 1.6 Nocturia episodes/day, mean ± SD: G1: 1.1 ± 1.0 G2: 1.4 ± 1.0 G3: 0.8 ± 0.7 Voids per day, mean ± SD: G1: 7.8 ± 2.8 G2: 8.0 ± 1.7 G3: 8.4 ± 2.5 OAB-q total HRQL, mean ± SD: G1: 73.1 ± 17.4 G2: 69.5 ± 24.6 G3: 71.6 ± 21.5 OAB-q severity, mean ± SD: G1: 47.0 ± 16.2 G2: 42.3 ± 17.7 G3: 45.9 ± 18.7 OAB-q coping, mean ± SD: G1: 72.0 ± 21.6 G2: 66.2 ± 31.7 G3: 73.8 ± 26.2 OAB-q concern, mean ± SD: G1: 68.2 ± 19.0 G2: 68.8 ± 27.6 G3: 63.8 ± 29.2 OAB-q sleep, mean ± SD: G1: 63.1 ± 28.7 G2: 59.8 ± 29.9 G3: 55.1 ± 27.6 OAB-q social, mean ± SD: G1: 92.5 ± 14.6 G2: 85.4 ± 19.9 G3: 92.8 ± 18.6 SF-12 quality of life, physical, mean ± SD: G1: 49.0 ± 9.6 G2: 41.7 ± 11.5 G3: 46.2 ± 10.6 SF-12 quality of life, mental, mean ± SD: G1: 49.1 ± 9.3 G2: 53.1 ± 8.8 G3: 46.3 ± 8.3 | Urgency episodes/day, 3 mos, mean ± SD: G1: 2.2 ± 1.8 G2: 1.5 ± 2.1 G3: 1.7 ± 1.8 Urgency episodes/day, 12 mos, mean ± SD: G1: 2.3 ± 2.5 G2: 1.9 ± 2.1 G3: 2.0 ± 1.1 Incontinence episodes/day, 3 mos, mean ± SD: G1: 0.8 ± 0.8 G2: 0.1 ± 0.3 G3: 0.6 ± 0.8 Incontinence episodes/day, 12 mos, mean ± SD: G1: 0.9 ± 0.0 G2: 0.9 ± 1.0 G3: 0.8 ± 0.7 Nocturia episodes/day, 3 mos, mean ± SD: G1: 1.0 ± 0.5 G2: 0.8 ± 0.7 G3: 0.6 ± 0.5 Nocturia episodes/day, 12 mos, mean ± SD: G1: 1.0 ± 0.9 G2: 1.2 ± 0.6 G3: 0.7 ± 0.7 Voids/day, 3 mos, mean ± SD: G1: 6.7 ± 1.8 G2: 6.3 ± 1.6 G3: 6.7 ± 2.2 Voids/day, 12 mos, mean ± SD: G1: 7.2 ± 1.1 G2: 6.8 ± 1.4 G3: 7.6 ± 1.5 OAB-q total HRQL, 3 mos, mean ± SD: G1: 82.3 ± 16.1 G2: 89.6 ± 9.4 G3: 91.8 ± 7.4 OAB-q total HRQL, 12 mos, mean ± SD: G1: 87.9 ± 11.6 G2: 81.6 ± 19.3 G3: 88.9 ± 9.9 OAB-q severity, 3 mos, mean ± SD: G1: 37.2 ± 22.0 G2: 16.8 ± 12.0 G3: 21.6 ± 10.9 OAB-q severity, 12 mos, mean ± SD: G1: 24.6 ± 10.6 G2: 33.1 ± 16.6 G3: 21.9 ± 14.8 OAB-q coping, 3 mos, mean ± SD: G1: 79.2 ± 22.1 G2: 91.6 ± 9.5 G3: 92.7 ± 9.4 OAB-q coping, 12 mos, mean ± SD: G1: 89.2 ± 13.7 G2: 81.5 ± 23.7 G3: 90.5 ± 10.0 OAB-q concern, 3 mos, mean ± SD: G1: 78.6 ± 18.0 G2: 87.7 ± 14.5 G3: 90.2 ± 12.4 OAB-q concern, 12 mos, mean ± SD: G1: 85.3 ± 15.5 G2: 81.7 ± 19.7 G3: 85.2 ± 13.4 OAB-q sleep, 3 mos mean ± SD: G1: 77.7 ± 24.9 G2: 81.3 ± 14.6 G3: 85.0 ± 19.6 OAB-q sleep, 12 mos, mean ± SD: G1: 79.9 ± 18.3 G2: 72.0 ± 24.5 G3: 83.2 ± 18.4 OAB-q social, 3 mos, mean ± SD: G1: 96.4 ± 9.7 G2: 95.6 ± 7.0 G3: 98.9 ± 1.9 OAB-q social, 12 mos, mean ± SD: G1: 97.3 ± 7.1 G2: 91.9 ± 14.2 G3: 97.3 ± 6.9 SF-12 quality of life, physical G1: 50.6 ± 8.0 G2: 42.1 ± 12.7 G3: 48.4 ± 10.8 SF-12 quality of life, physical, 12 mos, mean ± SD: G1: 50.0 ± 7.3 G2: 45.1 ± 13.9 G3: 45.3 ± 13.4 SF-12 quality of life, mental, 3 mos, mean ± SD: G1: 50.4 ± 9.6 G2: 51.2 ± 9.5 G3: 46.7 ± 7.6 SF-12 quality of life, mental, 12 mos, mean ± SD: G1: 49.6 ± 7.5 G2: 50.1 ± 10.7 G3: 50.6 ± 8.4 Dry mouth, n (%): G1: 3 (21) G2: 5 (46) G3: 5 (42) Headaches, n (%): G1: 6 (43) G2: 1 (11) G3: 7 (58) Dizziness, n (%): G1: 4 (29) G2: 2 (20) G3: 3 (25) Constipation, n (%): G1: 3 (21) G2: 3 (27) G3: 3 (27) Fatigue, n (%): G1: 9 (64) G2: 5 (46) G3: 7 (64) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Method and blinding: − Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: + Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Lee et al., 2002 Country and setting: South Korea, University Enrollment period: NR Funding: Pharmacia Corp Author industry relationship disclosures: NR | Design: RCT Intervention: Tolterodine 2mg bid vs. Oxybutynin 5mg bid Groups: G1: Tolterodine 2mg bid G2: Oxybutynin 5mg bid N at enrollment: G1: 112 G2: 116 N at follow-up: G1: 97 G2: 90 Women, n (%): G1: 84 (74) G2: 92 (79) Age, mean (range): G1: 52 (27, 82) G2: 52 (20, 86) Race/ethnicity (%): Asian: G1: 100 G2: 100 BMI, kg/m^2^ (range): G1: 23 (17, 32.5) G2: 23.5 (16, 38) Previous drug therapy: N (%) G1: 36 (32) G2: 26 (22) | Inclusion criteria: • Age ≥ 18 • OAB symptoms > 6 mos • ≥ 8 voids/day, with or without incontinence (measured by diary) Exclusion criteria: • SUI • Women not using reliable contraception • Pregnant or nursing • Prior treatment with anticholinergic < 2 wks • Renal or hepatic disease • Narrow angle glaucoma • Urinary retention • Gastric retention • Hypersensitivity to drugs • UTI • IC • Hematuria • BOO • Concomitant bladder training, e-stim treatment • Indwelling catheter • Intermittent catherization • Concomitant treatment for OAB ≤ 2 mos | Incontinence episodes/day, mean (range): G1: 2.6 (0.3, 9.3) G2: 2.4 (3.0, 14.7) Patients with incontinence episodes, n (%): G1: 46 (41) G2: 42 (36) Voids/day, mean (range): G1: 12.2 (8.0, 23.7) G2: 12.4 (7.7, 29.7) | Incontinence episodes/day, mean change ± SD (% change): G1: −2.2 ± 2.3 (−85) G2: −1.4 ± 1.8 (−58) G1/BL: P = 0.0001 G1/BL: P = 0.0001 G1/G2: P = 0.10 Voids/day, mean change ± SD (% change): G1: −2.6 ± 2.9 (−21) G2: −1.8 ± 4.2 (−15) G1/BL: P = 0.0001 G1/BL: P = 0.0001 G1/G2: P = 0.14 Benefit of Tx, %: G1: 45 G2: 46 G1/G2: P = NS Patients reporting adverse events, n (%): G1: 62 (55) G2: 94 (82) Discontinued due to AEs, n (%): G1: 11 G2: 18 Dry mouth, n (%): G1: 39 (35) G2: 72 (63) G1/G2: P = 0.001 Dry mouth, mild, n (%): G1: 29 (26) G2: 40 (35) Dry mouth, moderate, n (%): G1: 9 (8) G2: 26 (23) Dry mouth, severe, n (%): G1: 1 (1) G2: 6 (5) Voiding disorder, n (%): G1: 10 (9) G2: 16 (14) Dyspepsia, n (%): G1: 8 (7) G2: 6 (5) Abdominal pain, n (%): G1: 6 (5) G2: 6 (5) Headache, n (%): G1: 4 (4) G2: 6 (5) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Macaulay et al., 1987 Country and setting: UK, Specialty treatment center Enrollment period: NR Funding: Wellcome Trust, trustees of St. George’s Hospital Author industry relationship disclosures: NR | Design: RCT (randomization not specified) Intervention: Brief eclectic psychotherapy, bladder training or medication Groups: G1: psychotherapy G2: bladder drill G3: propantheline N at enrollment: G1: 19 G2: 16 G3: 15 N at follow-up: G1: 18 G2: 15 G3: 14 Women, %: 100 Age: NR Race/ethnicity: NR Follow-up: 3 months | Inclusion criteria: • Previous completion of survey on psych conditions w/OAB • Detrusor instability on UDS or sensory urgency Exclusion criteria: NR | Detrusor instability, n: G1: 10 G2: 8 G3: 8 Sensory urgency, n: G1: 9 G2: 8 G3: 7 Voids/day, mean: G1: NR G2: NR G3: 10.8 Bladder capacity (mL), mean: G1: 393 G2: NR G3: 323 Bladder volume (mL), first sensation, mean: G1: 107 G2: 110 G3: 70 Detrusor pressure rise (cm H_2_O), mean: G1: NR G2: 45.5 G3: NR | Voids/day, mean: G1: NR G2: NR G3: 8.3 G3/BL: P < 0.005 Bladder capacity (mL), mean: G1: 414 G2: NR G3: 368 G1/BL: P = NS G3/BL: P = NS Bladder volume (mL), first sensation, mean: G1: 142 G2: 150 G3: 137 G1/BL: P = NS G2/BL: P < 0.05 G3/BL: P = 0.06 Detrusor pressure rise (cm H_2_O), mean: G1: NR G2: 29.5 G3: NR G2/BL: P < 0.05 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: − Masking: − Pt selection criteria: − Loss to followup: ++ Drop-out rates: ++ Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: −, NR Baseline OAB status: NR Baseline characteristics: − Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Mattiasson et al., 2003 Country and setting: Sweden, Denmark, Norway (Tolterodine Scandinavian Study Group) Enrollment period: October 1999 to December 2000 Funding: Pharmacia Corp Author industry relationship disclosures: NR | Design: RCT, single-blinded (balanced blocks of 4, computerized randomization list) Intervention: Pharmacologic ± behavioral therapy; Tolterodine 2mg b.i.d. ± BT; Tolterodine dosage could be decreased to 1mg P.O. b.i.d. during the first 2 wks if intolerable SE; BT taught with a written handout Groups: G1: Tolterodine + BT x 24 wks G2: Tolterodine x 24 wks N at enrollment: Total: 505 N at follow-up: G1: 244 G2: 257 N Completed treatment: G1: 77% G2: 79% Total: 74% Women, n (%) G1: 177 (73) G2: 201 (78) Age, median (range): G1: 62 (19, 86) G2: 63 (22, 86) Race/ethnicity: NR Follow-up: 24 weeks | Inclusion criteria: • Age ≥ 18 • ≥ 8 voids/day and urinary urgency (± UUI) as determined by 1 wk bladder diary • With or without UUI • Women of reproductive age had to be using reliable birth control Exclusion criteria: • Contraindication to antimuscarinic therapy • Use of electrostimulation therapy or BT within prior 3 mo • Indwelling catheter or intermittent catheterization • Pregnancy or lactation • Use of anticholinergic agents or concomitant treatment for OAB (estrogen permitted) | Urgency episodes/day, mean (range): G1: 6.0 (0, 23.0) G2: 6.6 (0, 34.3) Incontinence episodes/day, mean (range): G1: 2 (0.3, 20.3) G2: 2.3 (0.3, 16.3) Voids/day, mean (range): G1: 10.3 (7.3, 27.6) G2: 10.6 (7.7, 24.6) Duration of symptoms > 5 years, n (%): G1: 120 (49) G2: 124 (48) Previous drug therapy for OAB, n (%): G1: 40 (160 G2: 35 (14) Previous surgery affecting lower urinary tract, n (%): G1: 28 (11.5) G2: 30 (12) Symptoms caused at least moderate problems, %: G1: 92 G2: 93 | Urgency episodes/day, median % change (IQR): G1: −38 (−76.7, −14.1) G2: −38 (−68.7, −8.0) G1/G2: P = 0.75 Incontinence episodes/day, median IQR% change; n=301: G1: −87 (−100, −20) G2: −81 (−100, −41.8) G1/G2: P = 0.28 Voids/day, median % change (IQR): G1: −33 (−42.3, 21.3) G2: −25 (−38.8, −13.0) G1/G2: P < 0.001 Voided volume (mL), median % change (IQR): G1: 31.5 (13.3, 56.2) G2: 20 (3.1, 45.4) G1/G2: P <0.001 Symptoms are “minor or less”, %: G1: 66.5 G2: 61.5 Overall improvement in symptoms, %: G1: 76 G2: 71 Worsening of symptoms, %: G1: 3 G2: 5 Dry mouth, n (%): G1: 76 (31) G2: 90 (35) Headache, n (%): G1: 15 (6) G2: 21 (8) Constipation, n (%): G1: 7 (3) G2: 14 (5) ≥ 1 SE, n (%): G1: 158 (65) G2: 177 (69) G1/G2: P = NS Withdrawal due to, %: AE: 15 Withdrawal due to lack of efficacy: 3 Withdrawal of consent: 2 Protocol violations: 1 Completed treatment: G1: 77% G2: 79% | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Millard, 2004 Country and setting: International, Multicenter study, 54 sites Enrollment period: NR Funding: Pharmacia Corp Author industry relationship disclosures: NR | Design: RCT Intervention: Tolterodine ± simplified pelvic-floor exercise regimen for 24 weeks Groups: G1: tolterodine 2 mg b.i.d. and simple PFME program G2: tolterodine 2 mg b.i.d. daily N at enrollment: G1: 227 G2: 253 N at follow-up, 12 weeks, n (%): G1: 181 (79.7) G2: 205 (81.0) N at follow-up, 24 weeks, n (%): G1: 164 (72.2) G2: 190 (75.1) Women, n (%): G1: 169 (75.4%) G2: 190 (75.4%) Age, mean ± SD: G1: 53.6 ± 16.9 G2: 53.2 ± 17.4 Race/ethnicity: Asian: G1: 176 (78.6%) G2: 203 (80.6% White/mixed: G1: 48 (21.4%) G2: 49 (19.4%) | Inclusion criteria: • Age 18–90 • ≥ 8 voids/day • Urgency • ≥ 1 UI episode/d • Sx for ≥ 6 months Exclusion criteria: • Symptomatic SI • Significant PVR volume • Neuropathy • Glaucoma • UTI • + urine cytology • Use of concomitant anticholinergic therapy w/in 14 days of randomization | Urgency episodes/day, mean ± SD: G1: 4.2 ± 3.6 G2: 4.1 ± 4.0 Urgency episodes/day, median (IQR): G1: 3.6 (1.3, 6.0) G2: 3.0 (1.3, 6.0) Incontinence episodes/day, mean ± SD: G1: 3.44 ± (3.4) G2: 3.21 ± (3.4) Incontinence episodes/day, median (IQR): G1: 2.3 (1.3, 4.0) G2: 2.9 (1.3, 3.7) Voids/day, mean ± SD: G1: 11.87 ± 4.3 G2: 12.78 ± 5.6 Voids/day, median (IQR): G1: 10.7 (9.0, 13.7) G2: 11.3 (9.0, 15.0) Voided volume (mL), mean ± SD: G1: 146.1 ± 67.7 G2: 146.0 ± 83.3 Voided volume (mL), median (IQR): G1: 137 (98, 186) G2: 132 (99, 189) Duration of symptoms, n (%): ≤ 5 years: G1: 166 (74.1) G2: 173 (68.7) > 5 years: G1: 56 (25) G2: 78 (31) Previous UT surgery, n (%): G1: 44 (19.6) G2: 43 (17.1) Prev antichol-inergics, n (%): G1: 19 (8.5) G2: 14 (5.6) Prev UUI drug, n (%): G1: 101 (45.1) G2: 91 (36.1) Patient sub-jective rating of UI symptoms as “severe” or “many severe”, %: G1: 54.0 G2: 56.8 | Urgency episodes/day, wk 12, mean change ± SD (% change): G1: −1.9 ± 4.0 (−64.5) G2: −2.2 ± 3.6 (−69.8) G1/BL: P = 0.001 G1/BL: P = 0.001 G1/G2: P = NS Urgency episodes/day, wk 12, median change: G1: −1.6 G2: −1.3 G1/G2: P = 0.7658 Urgency episodes/day, wk 24, mean change ± SD (% change): G1: −2.2 ± 3.6 (−78.7) G2: −2.7 ± 3.5 (−83) G1/BL: P = 0.001 G1/BL: P = 0.001 G1/G2: P = NS Urgency episodes/day, wk 24, median change: G1: −1.9 G2: −2.0 G1/G2: P = 0.3029 Incontinence episodes/day, wk 12, mean change ± SD: G1: −2.15 ± 3.0 G2: −2.15 ± 2.7 G1/BL: P = 0.001 G1/BL: P = 0.001 G1/G2: P = 0.2215 Incontinence episodes/day, wk 12, median change: G1: −1.6 G2: −1.6 G1/G2: P = 0.8251 Incontinence episodes/day, wk 24, mean change ± SD (% change): G1: −2.23 ± 3.0 (−64) G2: −2.26 ± 3.0 (−70) G1/BL: P = 0.001 G1/BL: P = 0.001 G1/G2: P = NS Incontinence episodes/day, wk 24, median change: G1: −1.6 G2: −1.6 G1/G2: P = 0.8341 Voids/day, wk 12, mean change ± SD (% change): G1: −2.68 ± 3.8 (−22) G2: −3.42 ± 4.6 (−26) G1/BL: P = 0.001 G1/BL: P = 0.001 G1/G2: P = 0.9478 Voids/day, wk 24, mean change ± SD (% change): G1: −2.58 ± 5.0 (−22) G2: −3.58 ± 5.2 (−26) G1/BL: P = 0.001 G1/BL: P = 0.001 G1/G2: P = 0.3549 Voided volume (mL), wk 12, median change (% change): G1: 20.4 (17.2) G2: 17.5 (15.8) Voided volume (mL), wk 12, median change (% change): G1: 21.1 (18.1) G2: 19.1 (15.4) Patient subjective report of improvement in bladder condition, wk 12, %: G1: 82.6 G2: 83.9 Patient subjective report of improvement in bladder condition, wk 24, %: G1: 81.7 G2: 85.9 Adverse events, n (%): G1: 22 (9.7) G2: 23 (9.1) Mild dry mouth, %: G1: 18.1 G2: 21.3 Moderate dry mouth, %: G1: 7.5 G2: 5.1 Severe dry mouth, %: G1: 4.0 G2: 3.2 Headache, %: 6 Constipation, %: 4.8 Nausea, %: 2.7 Dry eyes, %: 2.5 Dizziness, %: 2.4 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: - Masking: - Pt selection criteria: + Loss to followup: ++ Drop-out rates: - Power calculation: + Statistical issues: - EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Sand et al., 2004 Country and setting: US, Specialty clinic Enrollment period: Subanalysis of OBJECT trial, women only Funding: ALZA Corp Author industry relationship disclosures: NR | Design: RCT Intervention: 10mg ER Oxybutynin daily vs. 4mg Tolterodine (2mg bid) Groups: G1: 10mg ER Oxybutynin daily x 12 wks G2: 4mg Tolterodine (2mg bid) x 12 wks Stratified by age: a: Age ≤ 64 b: Age 65–74 c: Age ≥ 75 N at enrollment: G1: 152 G2: 163 N at follow-up: G1: 132 G2: 146 Women, %: 100 Age, yrs ± SD: G1: 58.4 G2: 58.8 Race/ethnicity: NR | Inclusion criteria: • ≥ 7 and ≤ 50 UUI episodes/week • ≥ 10 voids/day • MUI included if predominant UUI Exclusion criteria: • UTI • IC • Urethral diverticulum • Bladder tumor • Bladder stone • Delivery within 6 mos • Pelvic, bladder, vaginal surgery in ≤ 6 mos • PVR ≥ 150 mL • Cardiovascular, renal, pulmonary, gastrointestinal, endocrine, neurologic, autoimmune, hematological, urological, psychiatric, or hepatic disease • Hematuria • Positive urine culture • Narrow angle glaucoma • Obstructive uropathy • Myasthenia gravis • POP to hymenal ring • GI obstruction • Decreased GI motility • GI narrowing • GI retention • Investigational drugs within 1 month of screening • Hypersensitivity to drugs • Current drug/EtOH abuse • Pregnant • Breastfeeding • Inability to follow protocol | UUI episodes/week, mean: G1: 25.2 G2: 25.1 Incontinence episodes/week, mean: G1: 28.1 G2: 28.9 Voids/week, mean: G1: 91.7 G2: 91.6 Naïve to anti-cholinergics, %: G1: 60.5 G2: 60.7 | UUI episodes/week, %: G1: 6.2 G2: 8.5 G1a: 5.0 G2a: 8.4 G1b: 5.5 G2b: 7.5 G1c: 8.5 G2c: 11.1 G1/G2: P = 0.038 G1a/G2a: P = 0.005 G1b/G2b: P = 0.337 G1c/G2c: P = 0.568 Incontinence episodes/week, mean: G1: 7.3 G2: 10.1 G1a: 5.8 G2a: 10.0 G1b: 6.1 G2b: 9.2 G1c: 10.5 G2c: 12.5 G1/G2: P = 0.030 G1a/G2a: P = 0.005 G1b/G2b: P = 0.164 G1c/G2c: P = 0.714 Voids/week, mean: G1: 68.0 G2: 71.2 G1a: 63.7 G2a: 71.2 G1b: 73.8 G2b: 71.9 G1c: 66.8 G2c: 65.5 G1/G2: P = 0.272 G1a/G2a: P = 0.024 G1b/G2b: P = 0.706 G1c/G2c: P = 0.838 Dry mouth, %: G1: 28.3 G2: 33.7 Constipation, %: G1: 8.6 G2: 6.7 Retention, %: G1: 4.0 G2: 1.2 Blurred vision, %: G1: 2.6 G2: 0.6 Dizziness, %: G1: 3.9 G2: 4.3 Insomnia, %: G1: 0.7 G2: 1.8 Somnolence, %: G1: 3.3 G2: 1.8 Nervousness, %: G1: 0 G2: 1.2 Headache, %: G1: 9.2 G2: 10.4 Dyspepsia, %: G1: 5.3 G2: 6.1 Nausea, %: G1: 3.3 G2: 1.8 Vomiting, %: G1: 2.0 G2: 1.8 | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: - Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Schmidt et al., 1999 Country and setting: 16 centers in US, Canada, and Europe Enrollment period: 1993– April 1997 Funding: Medtronics Inc. Author conflict of interest: Schmidt, Jonas, Oleson, Janknegt, Siegel: financial interest and/or other relationship with Medtronic Inc. | Design: randomized controlled trial Intervention: implantable Interstim system stimulating the nerve ramus in preoperatively tested sacral nerve foramen Groups: G1: implantation with immediate stimulation (n=34 for efficacy analysis) G2: control group receiving standard medical therapy for 6 months; allowed to cross over at 6 months if remained eligible for implantation (n=42 for efficacy analysis) N at enrollment: 155 N randomized: 98 (the remaining 57 did not respond to test stimulation so were not randomized) N at follow-up: 76 at 6 months Age: mean 46.6 ±13.0 (range 20.2 – 78.9) Gender: 125 F (80.6%), 30 M (19.4%) Race/ethnicity: NR | Inclusion criteria: • age > 16 years • refractory to standard medical therapy • ≥ 100 mL bladder capacity with normal upper urinary tract • good surgical candidate • able to complete study documentation and return for follow-up evaluation Exclusion criteria: • Neurological conditions • Stress urinary incontinence • Primary pelvic pain | Duration of urinary symptoms before enrollment: mean 9.0±7.4 (range 0.6–35.4) Mean number of daily incontinence episodes: 8.9± 5.9 G1: 9.7 ± 6.3 G2: 9.3 ± 4.8 Mean leak severity rating: 1.9± 0.6 G1: 2.0 ± 0.7 G2: 1.8 ± 0.6 Mean absorbent pads/diapers replaced daily 4.8± 4.8 G1: 6.2 ± 5.0 G2: 5.0 ± 3.7 Mean heavy incontinence episodes per day: G1: 3.4 ±3.8 G2: 2.6 ±3.5 3-day diary data: 90.3% of patients had at least 1 moderate/heavy and 74.8% had at least 1 heavy incontinence episode Previous treatment for urinary problems: 153 (89.7%), including pharmacological in 144 (92.5%, nonsurgical in 55 (35.5%), and surgical in 88 (56.8%) | At 6 months: Mean number of daily incontinence episodes: G1: 2.6± 5.1 (p<0.0001) G2: 11.3 ± 5.9 (p=0.002) Mean leak severity rating: G1: 0.8 ± 0.9 (p<0.0001) G2: 2.0± 0.6 (p=0.006) Mean absorbent pads/diapers replaced daily G1: 1.1 ± 2.0 (p<0.0001) G2: 6.3 ± 3.6 (p=0.003) Mean heavy incontinence episodes per day: G1: 0.3 ±0.9 (P<0.0001) G2: 3.9 ±3.8 G1: 47% completely dry at 6 months; 3 patients had no reduction in incontinence after 6 months (one underwent device explantation and 2 had increased frequency of urination and incontinence) Safety data (pooled for 157 patients): adverse events requiring surgical repositioning or replacement of implant devices document in 51 (32.5%) 168 post-implant events reported by 83 patients, including pain at the neurostimulator site in 15.9%, pain at implant site in 19.1, and lead migration in 7.0% Infection or skin irritation led to device explantation in 2 patients and temporary explant in 2 patients No permanent injuries or nerve damage reported. | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: − Pt selection criteria: + Loss to followup: − Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Song, et al., 2006 Country and setting: Korea, Medical Center Enrollment period: May 2001 to April 2002 Funding: NR Author industry relationship disclosures: NR | Design: RCT Intervention: bladder training (BT) vs. Tolterodine vs. BT + Tolterodine Groups: G1: BT × 12 wks G2: Tolterodine 2 mg bid × 12 wks G3:Tolterodine 2 mg bid + BT × 12 wks N at enrollment: G1: 46 G2: 47 G3: 46 N at follow-up: G1: 26 G2: 32 G3: 31 Women, %: 100 Age, mean ± SD: G1: 45.73 ± 12.68 G2: 48.41 ± 9.38 G3: 45.42 ± 9.54 Race/ethnicity, %: Korean: 100 | Inclusion criteria: • Age ≥ 18 • ≥ 8 voids/day • Urge with or without incontinence • Symptom duration ≥ 3 months • No prior history of treatment for OAB Exclusion criteria: • Active urinary tract infection • Clinically significant SUI • Bladder outlet obstruction • Interstitial cystitis • Glaucoma • Megacolon • Maximal urine flow rate of < 10 mL/sec • Postvoid residual volume > 30% of the total amount voided on uroflowmetry | Voids/day, mean ± SD: G1: 10.93 ± 2.14 G2: 11.63 ± 2.57 G3: 11.90 ± 1.51 Nocturia episodes/day, mean ± SD: G1: 1.45 ± 1.14 G2: 1.72 ± 1.04 G3: 1.96 ± 1.49 Urgency, mean score ± SD: G1: 2.58 ± 1.30 G2: 2.81 ± 0.74 G3: 3.00 ± 1.10 Maximum flow rate (mL/s), mean ± SD: G1: 20.35 ± 8.44 G2: 22.56 ± 4.94 G3: 21.19 ± 4.96 Residual urine (mL), mean ± SD: G1: 9.08 ± 22.56 G2: 7.59 ± 12.39 G3: 6.42 ± 10.16 Symptom duration (years), mean ± SD: G1: 6.44 ± 6.84 G2: 4.54 ± 5.15 G3: 4.10 ± 3.99 | Voids/day, mean (% decrease) G1: 8.1 (25.9%)* G2: 8.1 (30.2%)* G3: 7.9 (33.5%)* G3/G1: P < 0.05 Nocturia episodes/day, mean (% reduction): G1: 0.6 (56.1%)* G2: 0.6 (65.4%)* G3: 0.6 (66.3%)* Urgency, mean score (% reduction): G1: 1.4 (44.8%)* G2: 1.1 (62.2%)* G3: 1.2 (60.2%)* G3/G1: P = 0.021 G2/G1: P = 0.017 G2/G3: P = NS Satisfaction, mean score (% improved): G1: 1.5 (53.9) G2: 1.4 (63.0) G3: 1.3 (71.0) Dry mouth, n (%): G1: 0 (0.0) G2: 7 (21.9) G3: 9 (28.9) Hesitancy, n (%) G1: 0 (0.0) G2: 3 (9.4) G3: 2 (6.5) Decreased appetite/constipation, n (%): G1: 0 (0.0) G2: 2 (6.3) G3: 2 (6.5) Headache, n (%): G1: 0 (0.0) G2: 1 (3.1) G3: 0 (0.0) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: − Pt selection criteria: + Loss to followup: − Drop-out rates: + Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Swift et al., 2003 Country and setting: Europe (167 centers), North America (74 centers), Australia and New Zealand (4 centers), University Enrollment period: February 1999 to October 1999 Funding: Pharmacia Corp Author industry relationship disclosures: NR | Design: RCT double blind placebo-controlled double dummy, random permuted blocks of 6 Intervention: Tolterodine ER vs. Tolterodine IR Groups: G1: Tolterodine ER 4mg daily G2: Tolterodine IR 2 mg BID G3: placebo N at enrollment: G1: 417 G2: 408 G3: 410 N at follow-up: Total: 1092 Women, %: 100 Age, yrs ± SD: G1: 59 ± 14 G2: 59 ± 14 G3: 60 ± 14 Race/ethnicity, n (%): White: G1: 396 (95) G2: 389 (95) G3: 383 (93) Black: G1: 15 (4) G2: 12 (3) G3: 20 (5) Asian/Pacific: G1: 5 (1) G2: 4 (1) G3: 2 (1) Mixed: G1: 0 G2: 3 (1) G3: 5 (1) Unknown: G1: 1 (<1) G2: 0 G3: 0 BMI, kg/m^2^ ± SD: G1: 28.8 ± 13.8 G2: 29.0 ± 11.0 G3: 28.8 ± 6.7 | Inclusion criteria: • Women • Age ≥ 18 • ≥ 8 voids/day • > 5 UUI/week • Symptoms × ≥ 6 months (per voiding diary) Exclusion criteria: • SUI • Total daily urine volume > 3 liters • Hepatic/renal disease • UTI • IC • Hematuria • BOO • Current e-stim • Current bladder training • Indwelling catheter • Intermittent catherization • Pregnant/nursing • Childbearing age without BC • Anticholinergic meds • Meds inhibit cytochrome P450 | Incontinence episodes/week, mean ± SD: G1: 22.1 ± 22.5 G2: 22.9 ± 21.9 G3: 23.9 ± 21.2 Pads/day, mean ± SD: G1: 1.6 ± 2.1 G2: 1.5 ± 2.0 G3: 1.7 ± 2.4 Voids/day, mean ± SD: G1: 10.8 ± 4.2 G2: 11.1 ± 3.7 G3: 11.2 ± 3.9 Voided volume (mL), mean ± SD: G1: 141.2 ± 43.1 G2: 137.2 ± 41.2 G3: 135.7 ± 43.2 Previous drug therapy: n (%): G1: 235 (56) G2: 222 (54) G3: 225 (55) | Incontinence episodes/week, mean ± SD: G1: 10.3 ± 17.2 G2: 12.8 ± 19.8 G3: 16.7 ± 19.7 G1/G3: P = 0.001 G2/G3: P = 0.001 Pads/day, mean ± SD: G1: 1.0 ± 1.8 G2: 1.0 ± 1.5 G3: 1.5 ± 2.2 G1/G3: P = 0.001 G2/G3: P = 0.001 Voids/day, mean ± SD: G1: 9.0 ± 3.2 G2: 9.3 ± 4.0 G3: 9.9 ± 3.8 G1/G3: P = 0.001 G2/G3: P = 0.005 Voided volume (mL), mean ± SD: G1: 179.1 ± 66.6 G2: 169.7 ± 65.6 G3: 149.0 ± 56.3 G1/G3: P = 0.001 G2/G3: P = 0.001 Clinical effecttiveness*, dry mouth: G1: 0.53 G2: 0.39 G3: 0.30 Dry mouth, n (%): G1: 105 (25.3) G2: 127 (31.2) G3: 33 (8.0) G1/G3: P < 0.01 G2/G3: P < 0.01 Abdominal pain, n (%): G1: 18 (4.3) G2: 12 (2.9) G3: 7 (1.7) G1/G3: P = 0.03 Flatulence, n (%): G1: 8 (1.9) G2: 11 (2.7) G3: 6 (1.5) Constipation, n (%): G1: 27 (6.5) G2: 27 (6.6) G3: 14 (3.4) Dyspepsia, n (%): G1: 11 (2.7) G2: 14 (3.4) G3: 6 (1.5) Nausea, n (%): G1: 7 (1.7) G2: 9 (2.2) G3: 9 (2.2) Diarrhea, n (%): G1: 10 (2.4) G2: 14 (3.4) G3: 9 (2.2) Xerophthalmia, n (%): G1: 16 (3.9) G2: 8 (2.0) G3: 8 (2.0) Abnormal vision, n (%): G1: 5 (1.2) G2: 4 (1.0) G3: 2 (0.5) Headache, n (%): G1: 29 (7.0) G2: 14 (3.4) G3: 19 (4.6) UTI, n (%): G1: 15 (3.6) G2: 11 (2.7) G3: 19 (4.6) Insomnia, n (%): G1: 7 (1.7) G2: 2 (0.5) G3: 9 (2.2) Somnolence, n (%): G1: 12 (2.9) G2: 11 (2.7) G3: 8 (2.0) Dizziness, n (%): G1: 7 (1.7) G2: 7 (1.7) G3: 4 (1.0) Hypertension, n (%): G1: 6 (1.4) G2: 4 (1.0) G3: 4 (1.0) Sinusitis, n (%): G1: 8 (1.9) G2: 2 (0.5) G3: 3 (0.7) Arthritis, n (%): G1: 1 (0.2) G2: 5 (1.2) G3: 1 (0.2) Dry skin, n (%): G1: 2 (0.5) G2: 5 (1.2) G3: 1 (0.2) | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: + Masking: + Pt selection criteria: + Loss to followup: ++ Drop-out rates: ++ Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Szonyi et al., 1995 Country and setting: UK Enrollment period: NR Funding: Smith & Nephew Pharmaceuticals Ltd Author industry relationship disclosures: NR | Design: RCT Intervention: Oxybutynin plus bladder training vs. placebo plus bladder training Groups: G1: Oxybutynin 2.5 mg bid with dose titration on days 29 and 43 plus bladder training G2: placebo + bladder training N at enrollment: G1: 30 G2: 30 N at follow-up: G1:16 G2: 23 Women, n (%): 56 (93) Age, mean ± SD: 82.2 ± 6.06 Race/ethnicity: NR Weight (kg), mean ± SD: 67.4 ± 14.92 | Inclusion criteria: • Age > 70 • Frequency, urgency and UUI • Mobile • Able to keep diary Exclusion criteria: • UTI • Hepatic or renal disease • Glaucoma • Uncontrolled diabetes • Taking imipramine or propantheline | | Voids/2 weeks, median change (95% CI): G1/G2: 577 (−27.0, 6.0) P = 0.0025 Nocturia episodes/2 weeks, median change (95% CI): G1/G2: −6 (−5, 7.0) Daytime incontinence episodes/2 weeks, median change (95% CI): G1 vs. G2: −9.5 (−11.0, 3.0) Nocturia episodes/2 weeks, median change (95% CI): G1/G2: −1.0 (−3.0, 2.0) Patient assessment of benefit, %: 29 days: G1: 86 G2: 55 P = 0.02 43 days: G1: 71 G2: 59 P = 0.41 57 days: G1: 79 G2: 55 P = 0.09 Patient response, 29 days, n: Cure: G1: 1 G2: 0 Significant improvement: G1: 15 G2: 8 Marginal improvement: G1: 7 G2: 8 No change: G1: 5 G2: 13 Patient response, 57 days, n: Cure: G1: 4 G2: 3 Significant improvement: G1: 14 G2: 8 Marginal improvement: G1: 3 G2: 4 No change: G1: 7 G2: 14 Dry mouth, %: G1: 93 G2: 86 Blurred vision, %: G1: 50 G2: 59 Heartburn, %: G1: 57 G2: 45 Constipation, %: G1: 50 G2: 45 Dry skin, %: G1: 50 G2: 59 Poor compliance (< 75% of tablets), %: G1: 20 G2: 20 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: + Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Tseng et al., 2009 Country and setting: Taiwan, University Enrollment period: January 2005 to November 2005 Funding: NR Author industry relationship disclosures: NR | Design: Prospective cohort randomized Intervention: Tolterodine 2 mg b.i.d. vs. tolterodine 2 mg b.i.d. + conjugated equine estrogen 0.625 mg twice per week Groups: G1: tolterodine 2 mg b.i.d. G2: tolterodine 2 mg b.i.d. + conjugated equine estrogen 0.625 mg twice per week N at enrollment: G1: 40 G2: 40 N at follow-up: G1: 40 G2: 40 Age, mean ± SD: G1: 64.5 ± 7.4 G2: 66.2 ± 6.8 Race/ethnicity: NR Women, N (%): G1: 40 (100) G2: 40 (100) BMI, kg/m^2^ ± SD: G1: 24.5 ± 3.9 G2: 25.3 ± 3.8 Previous antimuscarinic Rx, n (%): G1: 5 (12.5) G2: 6 (15) Prior hysterectomy, n (%): G1: 12 (30) G2: 14 (35) | Inclusion criteria: • Age ≥ 18 • OAB symptoms • Amenorrheic Exclusion criteria: • Advanced POP > > Stage 2 • Women with storage and voiding dysfunction undiagnosed • Severe constipation • Elevated PVR • Neurological deficit • Renal/hepatic disease • Narrow angle glaucoma • Urinary retention • Gastric retention • Hypersensitivity to drugs • BOO • Cardiac conduction disorders • Myasthenia gravis • History of CVA • History of VTE • Gallbladder disease • Known or suspected breast carcinoma • Undiagnosed genital bleeding • HRT within 3 months of study enrollment | UUI episodes/day, mean ± SD: G1: 1.8 ± 0.7 G2: 2.1 ± 1.1 Urgency episodes/day, mean ± SD: G1: 4.5 ± 0.8 G2: 4.3 ± 0.7 Nocturia episodes/day, mean ± SD: G1: 3.5 ± 0.8 G2: 3.3 ± 0.8 Voids/day, mean ± SD: G1: 14.1 ± 1.3 G2: 14.8 ± 1.5 UDI-6 score, mean ± SD: G1: 9.5 ± 3.9 G2: 8.6 ± 3.8 IIQ-7 score, mean ± SD: G1: 10.2 ± 4.5 G2: 9.4 ± 3.6 Voided volume (mL), mean ± SD: G1: 108.5 ± 14.0 G2: 115.8 ± 15.1 | UUI episodes/day, mean ± SD: G1: 1.5 ± 0.5 G2: 1.5 ± 0.5 P = NS Urgency episodes/day, mean ± SD: G1: 3.5 ± 0.5 G2: 3.3 ± 0.6 Nocturia episodes/day, mean ± SD: G1: 2.9 ± 0.6 G2: 2.6 ± 0.7 Voids/day, mean ± SD: G1: 6.4 ± 1.9 G2: 5.8 ± 0.9 P = 0.001 UDI-6 score, mean ± SD: G1: 7.2 ± 2.9 G2: 6.9 ± 2.7 P < 0.001 IIQ-7 score, mean ± SD: G1: 6.5 ± 2.7 G2: 6.1 ± 2.5 P < 0.001 Voided volume (mL), mean ± SD: G1: 134.5 ± 15.8 G2: 141.9 ± 16.1 P = 0.007 Adverse events: None | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: + Method and blinding: − Pt selection criteria: + Loss to followup: ++ Drop-out rates: ++ Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Van Kerrebroeck et al., 2001 Freeman et al., 2003* Country and setting: North America (74 centers), Australasia (4 centers), Europe (89 centers) Enrollment period: NR Funding: Pharmacia Corporation Author industry relationship disclosures: NR | Design: RCT Intervention: Tolterodine ER vs. Tolterodine IR vs. placebo Groups: G1: tolterodine ER 4 mg t.i.d. G2: tolterodine IR 2 mg b.i.d. G3: placebo N at enrollment: G1: 507 G2: 514 G3: 508 N at follow-up:<br>Total: 1442 G1: 398 G3: 374 Women, n (%): G1: 417 (82) G2: 408 (79) G3: 410 (81) Age, mean (range): G1: 60 (20, 89) G2: 60 (22, 92) G3: 61 (22, 93) Race/ethnicity, %:* White: G1: 95.7 G3: 94.7 Black: G1: 3.0 G3: 3.5 Asian/Pacific Islander: G1: 1.0 G3: 0.8 Other: G1: 0.3 G3: 1.1 | Inclusion criteria: • Age ≥ 18 • Urinary frequency (≥ 8 voids/day) Exclusion criteria: • SUI • Total daily urine volume > 3 L • Contra-indications to antimuscarinic treatment • Hepatic or renal disease • UTIs • Interstitial cystitis • Hematuria • BOO • Current electrostimulation or bladder training therapy • Indwelling catheter or intermittent self-catheterization • Pregnant or nursing • Women not using reliable contraception • Being treated for OAB with other anticholinergic drugs or drugs that inhibit cytochrome P450 3A4 isoenzymes • Estrogen therapy < 2 months • Treatment w/investigational drug < 2 months | Incontinence episodes/week, mean (range): G1: 22.1 (0, 168.0) G2: 23.2 (0, 168.0) G3: 23.3 (0, 168.0) ≥ 5 incontinence episodes/week, n (%): G1: 492 (97) G2: 498 (97) G3: 494 (97) Pads/day, mean (range): G1: 1.4 (0–18) G2: 1.4 (0–25) G3: 1.5 (0–22) Voids/day, mean (range): G1: 10.9 (2.3, 51.3) G2: 11.1 (2.0, 48.6) G3: 11.3 (2.0, 37.4) ≥ 8 voids/day, n (%): G1: 458 (90) G2: 469 (91) G3: 467 (92) Previous drug therapy, n (%): G1: 270 (53) G2: 276 (54) G3: 263 (52) Poor efficacy, %: G1: 43 G2: 38.4 G3: 40.7 Able to finish tasks before visiting a toilet, %:* G1: 5 G3: 6 Voided volume (mL), mean (range): G1: 141 (36, 338) G2: 137 (38, 283) G3: 136 (31, 374) | Urinary Urgency, subjective assessment, 12 wks, n (%):* Improvement: G1: 173 (44) G3: 118 (32) G1/G3: P < 0.001 No change: G1: 201 (51) G3: 212 (57) Deterioration: G1: 22 (6) G3: 44 (12) G1/G3: P < 0.002 Urinary urgency, improvement, 12 wks, women only, %:* G1: 46.6 G3: 26.6 G1/G3: P = 0.001 OR 1.81 (95% CI: 1.31, 2.49) Not able to hold urine, 12 wks, %:* G1: 58 G3: 32 G1/G3: P < 0.001 Incontinence episodes/week, mean change ± SD (%) G1: −11.8 ± 17.8 G2: −10.6 ± 16.9 G3: −6.9 ± 15.4 G1/G3: P = 0.00001 G2/G3: P = 0.0005 G1/G2: P < 0.05 Incontinence episodes/week, median % change: G1: −71 G2: −60 G3: −30 G1/G2: P < 0.05 Pads/day, mean ± SD: G1: −0.5 ± 1.4 G2: −0.5 ± 18 G3: −0.2 ± 1.4 G1/G3: P = 0.0145 G2/G3: P = 0.0035 Voids/day, mean ± SD: G1: −3.5 ± 4.9 G2: −3.3 ± 4.4 G3: −2.2 ± 4.0 G1/G3: P = 0.00001 G2/G3: P = 0.0002 Voluntary voids/day, mean ± SD: G1: −1.8 ± 3.4 G2: −1.7 ± 3.3 G3: −1.2 ± 2.9 G1 vs. G3 G1/G3: P = 0.00047 G2/G3: P = 0.0079 Bladder symptoms, improvement, 12 wks, women only, %:* G1: 62.8 G3: 48.4 G1/G3: P = 0.001 OR 1.78 (95% CI: 0.34, 2.37) Treatment benefit, 12 wks, n (%):* Much benefit: G1: 172 (43.2) G3: 88 (23.5) G1/G3: P < 0.001 Little benefit G1: 138 (34.7) G3: 118 (31.6) No benefit G1: 88 (22.1) G3: 168 (44.9) Able to finish tasks before visiting a toilet, 12 wks, %:* G1: 33 G3: 18 G1/G3: P < 0.001 Voided volume (mL), mean change ± SD: G1: +34 ± 51 G2: +29 ± 47 G3: +14 ± 41 G1/G3: P = 0.00001 G2/G3: P = 0.0001 Discontinued due to AEs, n (%): G1: 27 (5) G2: 28 (5) G3: 33 (6) Reported serious adverse events, n: G1: 7 G2: 12 G3: 18 Parasympathetic Dry mouth, n (%): G1: 118 (23) G2: 156 (30) G3: 39 (8) Xerophthalmia, n (%): G1: 17 (3) G2: 12 (2) G3: 10 (2) Abnormal vision, n (%): G1: 6 (1) G2: 4 (1) G3: 2 (0.5) Dry skin, n (%): G1: 2 (0.5) G2: 6 (1) G3: 1 (0.5) Gastrointestinal Constipation, n (%): G1: 30 (6) G2: 35 (7) G3: 22 (4) Dyspepsia, n (%): G1: 15 (3) G2: 16 (3) G3: 7 (1) Abdominal pain, n (%): G1: 19 (4) G2: 13 (3) G3: 8 (2) Diarrhea, n (%): G1: 10 (2) G2: 16 (3) G3: 11 (2) Flatulence, n (%): G1: 10 (2) G2: 14 (3) G3: 9 (2) Nausea, n (%): G1: 7 (1) G2: 10 (2) G3: 10 (2) Headache, n (%): G1: 32 (6) G2: 19 (4) G3: 23 (5) Somnolence, n (%): G1: 14 (3) G2: 13 (3) G3: 9 (2) Dizziness, n (%): G1: 11 (2) G2: 9 (2) G3: 5 (1) Fatigue, n (%): G1: 11 (2) G2: 6 (1) G3: 4 (1) Insomnia, n (%): G1: 7 (1) G2: 2 (0.5) G3: 9 (2) Urinary tract infection, n (%): G1: 16 (3) G2: 13 (3) G3: 20 (4) Dysuria, n (%): G1: 5 (1) G2: 8 (2) G3: 1 (0.5) Peripheral edema, n (%): G1: 7 (1) G2: 7 (1) G3: 4 (1) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: − Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Wang et al., 2006 Country and setting: Taiwan; Academic medical center Enrollment period: July 2004 to November 2005 Funding: National Science Council, Taiwan Author industry relationship disclosures: NR | Design: 12-wk RCT Intervention: Electric Stimulation (ES) vs. Oxybutynin vs. Placebo for 12 weeks Groups: G1: ES: intravaginal electrode; biphasic symmetric pulsed current w/a 10-Hz frequency, 400-millisecond pulse width, 10/5 duty cycle, and varying intensity, 20 min/session, twice weekly G2: Oxybutynin, 2.5 mg 3 times daily G3: Placebo pill 3 times daily N at enrollment: G1: 25 G2: 26 G3: 23 N at follow-up: G1: 24 G2: 23 G3: 21 Age: NR Race/ethnicity: NR | Inclusion criteria: • Female • OAB for ≥ 6 mos • Age 16–80 • Urgency ≥ 4 times per day Exclusion criteria: • Use of anticholinergics or TCAs • Previous treatment with pelvic-floor muscle training, bladder training • Pelvic prolapse repair • Pregnancy • Neurologic disorders • DM • Demand cardiac pacemaker • IUD use • Genital prolapse greater than ICS Stage II • PVR>100 mL • Overt SI • Anti-incontinence surgery • UTI | Warning time, s (range) G1: 41.5 (8–105) G2: 44 (2–215) G3: 65 (26–265 MVV, mL/void (range): G1: 340 (120–450) G2: 310 (130–800) G3: 350 (120–600) Daily voided volume, mL (range) G1: 2160 (1010–2950) G2: 2106 (1560–3153) G3: 2305 (1305–3300) Pads per day (range): G1: 1 (0–4.1) G2: 0 (0–3) G3: 1 (0–4) Urgency (subj): G1: 11.4 (4.0–16.0) G2: 12.1 (5–18) G3: 9.8 (4.2–15.5) Frequency (subj): G1: 12.8 (8.8–16.0) G2: 11.5 (4.3–19.5) G3: 11.5 (6.5–22.8) Nocturia (subj): G1: 1.75 (0–6.5) G2: 0 (0–2.5) G3: 0.65 (0–3.1) UI (subj): G1: 1 (0–2) G2: 0 (0–2) G3: 1 (0–2) | Warning time, s (range) G1: 72 (32–633) G2: 54.5 (138–850) G3: 66.5 (26–219) p-value (among 3 groups): <0.001 MVV, mL/micturition (range): G1: 355 (150–550) G2: 336.5 (138–850) G3: 340 (160–600) p-value (among 3 groups): 0.035 Voided volume/d, mL (range) G1: 2270 (1210–3106) G2: 2100 (1619–3200) G3: 2305 (1351–3221) p-value (among 3 groups): 0.050 Pad count, pad/d (range): G1: 0 (0–2) G2: 0 (0–2.5) G3: 1 (0–3) p-value (among 3 groups): 0.012 Urgency (subj) G1: 1.0 (0.0–12.3) G2: 6 (0.5–13) G3: 7.4 (3.9–13.4) p-value (among 3 groups): <0.001 Frequency (subj) G1: 7.8 (1.8–13.0) G2: 7.4 (2–14) G3: 10 (3.9–13.4) p-value (among 3 groups): 0.002 Nocturia (subj) G1: 0 (0–3.0) G2: 0 (0–2.5) G3: 1 (0–3.6) p-value (among 3 groups): 0.002 UI (subj) G1: 0.5 (0–2) G2: 0 (0–2) G3: 1 (0–2) p-value (among 3 groups): 0.413 P values before vs. after treatment Warning time, s (range): G1: 0.002 G2: 0.001 G3: 0.532 MVV, mL/void (range): G1: 0.018 G2: 0.004 G3: 0.979 Daily voided volume, mL (range): G1: 0.024 G2: 0.728 G3: 0.627 Pad per day (range): G1: 0.010 G2: 0.662 G3: 0.501 Urgency (subj): G1: <0.001 G2: <0.001 G3: 0.003 Frequency (subj): G1: <0.001 G2: <0.001 G3: 0.070 Nocturia (subj): G1: 0.001 G2: 0.394 G3: 0.176 UI (subj): G1: 0.814 G2: 0 083 G3: 0.854 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: − Pt selection criteria: + Loss to followup: ++ Drop-out rates: + Power calculation: + Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Zinner et al., 2005 Country and setting: US, Specialty treatment center Enrollment period: NR Funding: Pfizer Novartis Pharma Thomson ACUMED Author industry relationship disclosures: NR | Design: Randomized double- blind placebo- controlled four way crossover Intervention: Darifenacin 15 mg qd vs. darifenacin 30 mg qd vs. Oxybutynin vs. placebo Groups:* G1: Darifenacin 15mg daily G2: Darifenacin 30mg daily G3: Oxybutynin 5 mg t.i.d. G4: placebo N at enrollment: G1–G4: 76 N included, tolerability: G1–G4: 61 N included, efficacy: G1–G4: 58 Women, n (%): G1–G4: 71 (93.4) Age, mean (range): G1–G4: 59.9 (33–84) Race/ethnicity: NR Weight (kg), mean (range): G1–G4: 75.7 (42–157) | Inclusion criteria: • Age 18–85 • ≥ 4 UUI episodes/week • ≥ 8 voids/day (from 14 day run in placebo voiding diary) Exclusion criteria: • Neurogenic bladder • SUI • Contraindication to antimuscarinic treatment • UTI • Bladder symptoms • Bladder stones • BOO • Concomitant disease • Concurrent bladder training • Concurrent thyroid or HRT • Other bladder meds • Pregnant or breastfeeding | Urgency episodes/day, mean ± SD: G1–G 4: 9.3 ± 3.4 Urgency severity, mean ± SD: G1–G4: 2.0 ± 0.4 Incontinence episodes/week, mean ± SD: G1–G4: 20.4 ± 17.7 Voids/day, mean ± SD: G1–G4: 10.4 ± 3.0 | Urgency episodes/day, mean: G1: 7.95 G2: 7.59 G3: 8.12 G4: 8.71 G1–G3/G4: P < 0.05 Urgency severity, mean: G1: 1.93 G2: 1.84 G3: 1.89 G4: 2.03 G1–G3/G4: P < 0.05 Incontinence episodes/week, mean: G1: 10.93 G2: 8.82 G3: 9.45 G4: 14.64 G1–G3/G4: P < 0.05 Voids/day, mean ± SD: G1: 9.33 G2: 8.85 G3: 9.24 G4: 9.62 G2/G4: P < 0.05 Dry mouth, (%): G1: 13.1 G2: 34.4 G3: 36.1 G4: 4.9 G1/G3: P < 0.05 G2/G3: P < 0.05 G2/G4: P < 0.05 G3/G4: P < 0.05 Constipation, (%): G1: 9.8 G2: 21.3 G3: 8.2 G4: 3.3 G2/G3: P < 0.05 G2/G4: P < 0.05 Blurred vision, (%): G1: 0 G2: 0 G3: 3.3 G4: 0 Dizziness, (%): G1: 0 G2: 0 G3: 1.6 G4: 0 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: − Drop-out rates: NR Power calculation: + Statistical issues: + EXTERNAL VALIDITY: fair Age: −, NR Baseline OAB status: NR Baseline characteristics: − Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +

Note: 29.2 of G3 declined to continue with drug therapy once they received behavioral modification.

Evidence Table 7 KQ4 Modifiers of outcomes

Study Description | Study Design, Interventions, and Population | Inclusion/Exclusion Criteria | Symptom Characteristics | Outcomes | Quality Rating
Author: Anderson et al., 2006 [See evidence table for Diokno et al. 2003] Country and setting: US, Multicenter Enrollment period: NR Funding: NR Author industry relationship disclosures: 1 of 6 ALZA Corp (1) | Design: RCT Intervention: different extended release anticholinergic medications in women with or without prior anticholinergic treatment for OAB Groups: G1: Prior anticholinergic treatment G1a: ER oxybutynin 10 mg po daily G1b: ER tolterodine, 4mg po daily G2: No prior anticholinergic treatment G2a: ER oxybutynin 10 mg po daily G2b: ER tolterodine, 4mg po daily Ga: ER oxybutynin 10 mg po daily Gb: ER tolterodine, 4mg po daily N at enrollment: Total: 790 G1: 373 G1a: 180 G1b: 193 G2: 417 G2a: 211 G2b: 206 N at follow-up, 12 weeks: G1: 341 G1a: 165 G1b: 176 G2: 355 G2a: 174 G2b: 181 Women, %: 100 Age, mean ± SD: G1a: 62.6 ± 12.9 G1b: 62 ± 12.6 G2a: 57.5 ± 13.4 G2b: 58.8 ± 12.4 Race/ethnicity, %: White: G1a: 87 G1b: 88 G2a: 82 G2b: 84 Black: G1a: 7 G1b: 9 G2a: 9 G2b: 8.7 Asian: G1a: 0.6 G1b: 0 G2a: 0 G2b: 1 Hispanic: G1a: 5.6 G1b: 3.1 G2a: 8.1 G2b: 6.3 Other G1a: 0 G1b: 0.5 G2a: 0.9 G2b: 0 | Inclusion criteria: • Women • Age ≥ 18 • Mean of 21–60 UUI episodes per week and mean of ≥ 10 voids per 24 hr Exclusion criteria: NR | UUI episodes/wk, mean ± SD: G1a: 36.8 ± 16.4 G1b: 37.4 ± 14.0 G2a: 37.5 ± 14.0 G2b: 36.2 ± 13.9 Incontinence episodes/wk, mean ± SD: G1a: 41.5 ±19.0 G1b: 43.0 ± 18.0 G2a: 45.0 ±19.4 G2b: 41.9 ± 17.9 Voids/week, mean ± SD: G1a: 92.8 ± 23.7 G1b: 94.6 ± 25.2 G2a: 96.5 ± 27.1 G2b: 97.9 ± 24.2 | UUI episodes/wk, mean ± SD: G1a: 11.4 ± 17.9 G1b: 13.3 ± 15.1 G2a: 10.2 ± 13.7 G2b: 9.3 ± 13.3 G1a/G1b: P = 0.3 UUI episodes/wk, completed wk 12, mean ± SD: G1a: 9.9 ± 14.1 G1b: 12.9 ± 14.9 P = 0.049 No UUI, 12 wk, %: G1a: 25.2 G1b: 16.4 G2a: 29.4 G2b: 26.4 G1a/G1b: P = 0.046 G2a/G2b: P = 0.495 Incontinence episodes/wk, mean ± SD: G1a: 12.7 ± 18.7 G1b: 16.5 ± 19.8 G2a: 11.9 ± 15.1 G2b: 11.3 ± 16.0 G1a/G1b: P = 0.09 (P = 0.012 if completed wk 12) G2a/G2b: P = 0.886 Voids/week, mean ± SD: G1a: 68.4 ± 17.2 G1b: 72.8 ± 25.4 G2a: 64.8 ± 22.0 G2b: 69.4 ± 21.3 G1a/G1b: P = 0.05 (P = 0.026 iwk 12) G2a/G2b: P = 0.035 (P = 0.026 wk 12) Dry mouth, % G1a: 32 G1b: 19 G2a: 27.5 G2b: 25.2 G1a/G1b: P = 0.004 G2a/G2b: P = 0.6 Constipation, %: G1a: 7.8 G1b: 5.2 G2a: 5.2 G2b: 10.2 Diarrhea, %: G1a: 7.8 G1b: 5.7 G2a: 8.1 G2b: 6.8 Headache, %: G1a: 4.4 G1b: 5.2 G2a: 6.6 G2b: 6.8 Discontinued d/t AE, n (%): G1a: 7 (3.9) G1b: 6 (3.1) G2a: 13 (6.2) G2b: 13 (6.3) Withdrew, %: G1: 3.5 G2: 6.2 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: + Pt selection criteria: + Loss to followup: ++ Drop-out rates: ++ Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Appell, Abrams et al., 2001 Country and setting: Multinational, Multicenter Enrollment period: NR Funding: Pharmacia Author industry relationship disclosures: NR | Design: Open-label extension study (after 12-wk RCT and 1 wk washout) Intervention: Tolterodine 2 mg BID with option for patients to self-lower their dosage to 1mg bid Groups: NA N at enrollment: 854 N at follow-up, n (%): 594 (70) Age, yrs, mean (range): 59.5 (19–89) Race/ethnicity: NR Women, %: 76 Parity mean ± SD: NR Previous drug therapy for OAB, n (%) 472 (55) Previous lower urinary tract surgery, n (%) 291 (34) | Inclusion criteria: • 18+ years old • Cystometric evidence of detrusor overactivity (phasic detrusor contraction with amplitude 10+ cm H2O • ≥ 8 voids/day • ≥ 1+ urinary incontinence episode/day Exclusion criteria: • SUI • Hepatic or renal disease • UTI • IC • Hematuria • Contraindication to antimuscarinic therapy • Previous serious AE on oxybutynin • Voiding difficulty w/treatment of urinary retention • Treatment w/in 14 days prior to baseline visit • Initiation of antimuscarinic or any drug for UI during study • Electro-stimulation or bladder training • Indwelling or intermittent catheter • Total voided volume >3L/day | Detrusor instability, %: 93.7 Urge incontinence episodes, n (%): 724 (85) Symptom duration > 5 yrs, n (%): 412 (48) Urgency, n (%): 841 (98) Severe/very severe problems, n (%): 384 (45) voids/day, mean (range): 11.4 (5.3–37.0) Urge incontinence episodes/day, mean (range): 3.5 (0.1–24.0) Volume voided mean mL (range): 159 (25–423) Adverse events at end of 12-wk RCT, n (%): Any: 358 (76) ANS: 203 (43) CNS: 59 (12) GI: 125 (26) Respiratory: 68 (14) Urinary: 50 (11) Dry mouth: 187 (39) UTI: 26 (5) Headache: 49 (10) Constipation: 31 (7) Abdominal pain: 36 (8) URI: 28 (6) | Voids/day, 3 mos, mean (range) 8.8 (2.0–23.4) Voids/day, 3 months, mean change (95% CI): −2.6 (−2.8 to −2.3) P = 0.0001 Voids/day, 9 mos, mean (range): 8.9 (1.9–31.6) Voids/day, 9 months, mean change (95% CI): −2.5 (−2.9 to −2.4) P = 0.0001 Void frequency, 9 mos, median change: −22% Urge incontinence episodes/day, 3 mos, mean (range): 1.3 (0.0–24.0) Urge incontinence episodes/day, mean change (95% CI): −2.1 (−2.4 to −1.9) P = 0.0001 Urge incontinence episodes/day, 3 mos, mean (range): 1.5 (0.0–24.0) Urge incontinence episodes/day, mean change (95% CI): −2.0 (−2.2 to −1.7) P = 0.0001 Urge Incontinence episodes/day, median change, %: −76% Volume voided, 3 mos, mean mL (range): 201 (33–444) Volume voided, 3 mos, mean change mL (95% CI): +41 (36–45) P = 0.0001 Volume voided, 9 mos, mean change mL (range): 199 (34–514) Volume voided mean change mL (95% CI): +40 (35–45) P = 0.0001 Volume voided, 9 mos, median change, %: +22% Improvement, 9 mos, %: 65 Any adverse event, n (%): 652 (76) ANS, n (%): 268 (31) General, n (%): 219 (26) CNS/PNS, n (%): 82 (10) GI, n (%) 201 (24) Respiratory, n (%): 139 (16) Urinary, n (%): 165 (19) Dry mouth, n (%): 236 (28) Mild dry mouth, %: 19% Moderate dry mouth, %: 7% Severe dry mouth, %: 2% UTI, n (%): 106 (12) Headache, n (%): 57 (7) Constipation, n (%): 57 (7) Abdominal pain, n (%): 50 (6) Upper respiratory tract infection, n (%): 45 (5) Serious adverse events, n: 72 Discontinued due to AE, n (%): 73 (9) Reduced dosage to 1 mg bid, n (%): 108 (13%) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Capo et al. 2008 Country and setting: US, 207 centers Enrollment period: NR Funding: Astellas Pharma US, Inc., and GlaxoSmithKline Author industry relationship disclosures: 5/5 Astellas (4) Boehringer Mannheim Pharmaceuticals (1) Cephalon Inc. (1) GlaxoSmithKline (3) Reliant Pharmaceuticals (1) Schering Plough Corporation (1) Abbott (1) Akros (1) AstraZenica (1) Johnson & Johnson (1) Lilly (1) Manking (1) Merck (1) Novartis (1) NovoNordisk (1) Pfizer Inc. (1) Solvay (1) Takeda & TAP (1) Pri Med (1) Lucente (1) | Design: RCT Intervention: 12-wk treatment with 5 mg solifenacin succinate. Dosage could be increased at wk 4 and wk 8 to 10 mg, maintained or decreased in response to pt perceived efficacy and tolerability Groups: G1: Hispanic subgroup of G2 G2: full study population including G1 N at enrollment: G1: 94 G2: 2205 N at follow-up, range: G1: 47–80 G2: 1254–2005 Age, yrs ± SD: G1: 51.8 ± 12.8 G2: 59.7 ± 14.4 Weight in lbs, mean ± SD: G1: 171.1±36.4 G2: 182.2±47.0 Race/ethnicity, n (%) G1: Hispanic 94 (100) G2: White 1761 (79.9) Hispanic 94 (4.3) Black 274 (12.4) Asian 59 (2.7) Other 17 (0.8) Women, N (%): G1: 74 (78.7) G2: 1813 (82.2) Parity : NR | Inclusion criteria: • ≥ 18 yrs of age • OAB symptoms ≥3 mos • Toilet without difficulty • Washout of other OAB meds ≥ 7 days • Non-drug treatment of OAB if established ≥ 4 wks prior to study and continued Exclusion criteria: • SUI • Stress predominant MUI • UTI or chronic inflammation clinically significant outflow • Obstruction due to BPH • Narrow-angle glaucoma • Urinary or gastric retention • Severe renal or hepatic impairment • Chronic severe constipation or gastrointestinal obstructive disease • Bladder cancer • Women not using a reliable contraceptive • Hypersensitivity to the study medication, any of its components, or to anticholinergic medication | Urge incontinence, n (%): G1: 63 (67.0) G2: 1586 (71.9) Urinary urgency, n %: G1: 88 (93.6) G2: 2007 (91.0) Frequency, n, (%): G1: 86 (91.5) G2: 1969 (89.3) Nocturia, n (%): G1: 79 (84.0) G2: 1792 (81.3) Patient perception of bladder condition, mean score: G1: 4.0 G2: 4.0 Most bothersome OAB symptom-frequency, n %: G1: 38 (40.4) G2: 619 (28.1) Most bothersome OAB symptom-urinary urgency, n %: G1: 22 (23.4) G2: 508 (23.0) Most bothersome OAB symptom-urge incontinence, n %: G1: 17 (18.1) G2: 602 (27.3) Most bothersome OAB symptom-nocturia, n %: G1: 12 (12.8 G2: 337 (15.3) Most bothersome OAB symptom-none specified, n %: G1: 5 (5.3) G2: 139 (6.3) | Increased dosage 5 mg/day, n (%)-Wk 4: G1: 46 (48.9) Increased dosage 10 mg/day, n (%)-Wk 4: G1: 37 (39.4) Discontinued, n Wk 4: G1: 1 Increased dosage 5 mg/day, n (%)-Wk 8: G1: 31 (33.0) Increased dosage 10 mg/day, n (%)-Wk 8: G1: 39 (41.5) Discontinued-Wk 8, n: 1 Returned to 5 mg/day-Wk 8, n: 5 Increased dosage to 10 mg/day-Wk 8, n: 12 Patient Perception of Bladder, mean Wk 4: G1: 3.3* G2: 3.3* Patient Perception of Bladder, mean Wk 8: G1: 2.8* G2: 2.8* Patient Perception of Bladder, mean Wk 12: G1: 3.0* G2: 2.9* *P<0.001 vs BL Symptom bother from VAS, change from Baseline, mean scores (mm), p-value, CI: Urinary urgency: G1: −39.2 P<0.001, −45.9, −32.5 G2: −39.5 P<0.001, −41.0, −38.1 Urge Incontinence: G1: −37.7 P<0.001, −46.0, −29.4 G2: −40.1, P<0.001, −41.8, −38.4 Frequency: G1: −40.0 P<0.001, −46.9, −33.2 G2: −41.8 P<0.0001, −43.3, −40.3 Nocturia: G1: −43.2 P<0.001, −50.4, −36.1 G2: −36.9, −38.4, −35.4 OAB-q subscales at end-point, change from baseline, mean, p-value, CI: Symptom bother: G1: −29.1 P<0.001, −34.8, −23.4 G2: −29.6 P<0.001, −30.7, −28.6 Coping: G1: 24.0 P<0.001, 18.0, 30.1 G2: 27.4 P< 0.001 26.2, 28.5 Concern: G1: 25.8 P<0.001, 19.5, 32.2 G2: 29.6 P< 0.001, 28.4, 30.8 Sleep: G1: 25.7 P<0.001, 19.4, 32.0 G2: 27.3 P< 0.001, 26.1, 28.5 Social Interaction G1: 15.9 P<0.001, 11.5, 20.3 G2: 14.7 P< 0.001, 13.7, 15.6 Overall Health-related QoL: G1: 23.2 P<0.001, 18.0, 28.5 G2: 25.4 P< 0.001, 24.4, 26.4 Any Adverse Event, n (%): G1: 48 (51.4) G2: 1321 (59.4) Dry mouth, n (%): G1: 17 (18.1) G2: 477 (21.4) Constipation, n (%): G1: 12 (12.8) G2: 295 (13.3) Headache, n (%): G1: 3 (3.2) G2: 76 (3.4) Dizziness, n (%): G1: 2 (2.1) G2: 27 (1.2) Blurred vision, n (%): G1: 4 (4.3) G2: 57 (2.6) Palpitations, n (%): G1: 2 (2.1) G2: 6 (0.3) Upper respiratory tract infection, n (%): G1: 3 (3.2) G2: 68 (3.1) UTI, n (%): G1: 3 (3.2) G2: 76 (3.4) Bronchitis, n (%): G1: 3 (3.2) G2: 31 (1.4) Nasopharyngitis, n (%): G1: 2 (2.1) G2: 50 (2.3) Influenza, n (%): G1: 2 (2.1) G2: 11 (0.5) Insomnia, n (%): G1: 2 (2.1) G2: 17 (0.8) Depression, n (%): G1: 2 (2.1) G2: 19 (0.9) Hypertension, n (%): G1: 2 (2.1) G2: 16 (0.7) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: − Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: NR Baseline characteristics: − Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Dmochowski et al., 2002 Country and setting: US, Community Enrollment period: NR 2 week washout 12 week treatment period Funding: NR Author industry relationship disclosures: 7 of 7 Abbot (1) Alza (3) Amgen (1) AstraZeneca (1) Bayer (1) Bioform (1) Genyx (1) Glaxo (1) Interneuron (2) Lilly (2) Merck (1) Otsulta (1) Pharmacia (3) Pfizer (1) Praecis (2) Roche (1) Seprecor (1) Surx (1) Synthelabo (1) Vivus (1) Watson (7) Yamanouchi (1) | Design: RCT Followed by: 12 week open label dose titration Intervention: Oxybutynin TDS vs placebo Groups: G1: OXY TDS 1.3 mg G2: OXY TDS 2.6 mg G3: OXY TDS 3.9 mg G4: placebo N at enrollment: G1: 130 G2: 133 G3: 125 G4: 132 N at follow-up: G1: 128 G2: 131 G3: 123 G4: 130 Women, N (%): G1: 120 (92.3) G2: 123 (92.5) G3: 114 (91.2) G4: 121 (91.7) Age, mean ± SD: G1: 61.5 ± 11.8 G2: 61.9 ± 13.5 G3: 59.4 ± 14.5 G4: 62.7 ± 13.1 Race/ethnicity, n (%): White: G1: 119 (91.5) G2: 118 (88.7) G3: 118 (94.4) G4: 118 (89.4) Black: G1: 7 (5.4) G2: 10 (7.5) G3: 3 (2.4) G4: 11 (8.3) Other: G1: 4 (3.1) G2: 5 (3.8) G3: 4 (3.2) G4: 3 (2.3) | Inclusion criteria: • Age ≥ 18 • History of OAB • ≥ 10 episodes UUI either pure urge or predominant urge on 7 day voiding diary • ≥ 56 voids/7 day diary • Average recorded urinary volume of ≤ 350 mL Exclusion criteria: • Incontinence related to chronic illness • Concomitant medications • History of lower urinary tract surgery in ≥ 6 mos • IC • Urethral syndrome • Painful bladder syndrome • Overflow urinary incontinence • Alcohol/drug abuse • Known hypersensitivity to oxybutynin, similar compounds or transdermal systems • Active skin disorder • Narrow angle glaucoma • Excessive caffeine intake > 5 cups/day | Incontinence episodes/week, median: G1: 31.0 G2: 30.0 G3: 31.0 G4: 30.0 Voids/day, mean ± SD: G1: 12.4 ± 2.9 G2: 12.1 ± 3.3 G3: 12.3 ± 3.3 Voided volume (mL), mean: G1: 175 G2: 165 G3: 156 G4: 170 Open Label: Incontinence episodes/week, open label, median: G1: 30.0 G2: 29.0 G3: 37.0 G4: NA Prior years incontinent, years, mean ± SD: G1: 9.1 ± 10.3 G2: 8.9 ± 8.8 G3: 9.9 ± 9.8 G4: 9.1 ± 9.1 IIQ (QoL), total score, mean: G1: 167 G2: 161 G3: 144 G4: 160 Prior anticholinergic treatment, n, (%): G1: 30 (23.1) G2: 28 (21.1) G3: 28 (22.4) G4: 27 (20.5 | Incontinence episodes/week, median change: G1: −16.0 G2: −14.0 G3: −19.0 G4: −14.5 G3/G4: P < 0.0165 Voids/day, mean change ± SD: G1: −1.8 ± 2.6 G2: −1.8 ± 2.4 G3: −2.3 ± 2.5 G4: −1.7 ± 3.0 G3/G4: P = 0.0457 Voided volume, mL, mean increase ± SD: G1: −2 G2: 19 G3: 24 G4: 6 G3/G4: P = 0.0063 G2/G4: P = 0.0157 Open Label: Incontinence episodes/week, median change: G1: −18.0 G2: −17.0 G3: −19.0 G4: NA IIQ (QoL), total score, mean change: G1: 119 G2: 104 G3: 89 G4: 113 G3/G4: P = 0.0327 UDI (QoL), total score, mean ± SD: G1: NR G2: NR G3: 78.8 ± 51.9 G4: 94.7 ± 50.0 G3/G4: P = 0.0266 Dry mouth, n (%): G1: 6 (4.6) G2: 9 (6.8) G3: 12 (9.6) G4: 11 (8.3) Dizziness, n (%): G1: 2 (1.5) G2: 4 (3.0) G3: 5 (4.0) G4: 5 (3.8) Dysuria, n (%): G1: 1 (0.8) G2: 3 (2.3) G3: 3 (2.4) G4: 0 (0) Somnolence, n (%): G1: 1 (0.8) G2: 0 (0) G3: 2 (1.6) G4: 1 (0.8) Nausea, n (%): G1: 6 (4.6) G2: 5 (3.8) G3: 2 (1.6) G4: 7 (5.3) Constipation, (%): G1: 7 (5.4) G2: 3 (2.3) G3: 1 (0.8) G4: 4 (3.0) Palpitations, n (%): G1: 1 (0.8) G2: 0 (0) G3: 1 (0.8) G4: 0 (0) Vision abnormal, n (%): G1: 3 (2.3) G2: 2 (1.5) G3: 0 (0) G4: 2 (1.5) Localized application site reactions, n (%): G1: 32 (26.4) G2: 7 (5.7) G3: 8 (6.9) Application site erythema, n (%): G1: 23 (19) G2: 29 (23.6) G3: 14 (12.0)<br> Application site erythema, mild, double blind period, n (%): G1: 79 (31.5) G2: 29 (36.2) G3: NA Application site erythema, moderate, double blind period, n (%): G1: 46 (18.3) G2: 46 (18.1) G3: NA Application site erythema, severe, double blind period, n (%): G1: 6 (2.4) G2: 8 (3.1) G3: NA Application site erythema, mild, open label, n (%): G1: 18 (34.6) G2: 58 (38.4) G3: 87 (43.9) Application site erythema, moderate, open label, n (%): G1: 7(13.5) G2: 23 (15.2) G3: 24 (12.1) Application site erythema, severe, open label, n (%): G1: 0 (0) G2: 2 (1.3) G3: 0 (0) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Dmochowski et al. 2003 Country and setting: US; Community Enrollment period: NR 2 week washout 12 week treatment period Funding: Watson Pharma Author industry relationship disclosures: 6 of 6 Watson Pharma | Design: RCT Intervention: Oxybutynin TDS vs Tolterodine ER vs placebo, 2 week washout plus 12 weeks treatment period; drug/placebo applied transdermally twice weekly to the abdomen and oral capsule ingested once daily Groups: G1: OXY TDS 3.9 mg/day G2: Tolterodine ER 4 mg daily G3: placebo N at enrollment: G1: 121 G2: 123 G3: 117 Total: 361 N at follow-up: G1: NR G2: NR G3: NR Total: 320 (89%) Age, mean yrs ± SD: G1: 63.1 ± 12.0 G2: 62.9 ± 13.5 G3: 64.5 ± 12.3 Race/ethnicity, mean (%): White: G1: 111 (91.7) G2: 120 (97.6) G3: 110 (94.0) Race/ethnicity, mean (%): Black: G1: 8 (6.6) G2: 1(0.8) G3: 4 (3.4) Race/ethnicity, mean (%): Other: G1: 2 (1.6) G2: 2 (1.6) G3: 3 (2.6) Women, N (%): G1: 109 (90.1) G2: 117 (95.1) G3: 109 (93.2) Parity: NR Prior antimuscarinic treatment, Tolterodine, n, (%): G1: 57 (47) G2: 60 (49) G3: 54 (46) Prior antimuscarinic treatment, Oxybutynin, n, (%): G1:61 (51) G2: 59 (48) G3: 59 (50) Prior antimuscarinic treatment, Other, n, (%): G1: 7 (6) G2: 6 (5) G3: 6 (5) | Inclusion criteria: • ≥ 18yo men and women • Current pharmacological treatment for OAB with beneficial response • ≥4 episodes UUI episodes either pure urge or predominant urge on 3 day voiding diary • ≥ 24 voids/3 day diary • Average recorded urinary volume of ≤350 ml Exclusion criteria: • History of lower urinary tract surgery in previous 6 months • IC • Urethral syndrome • Painful bladder syndrome • Overflow urinary incontinence | Incontinence episodes/day, mean ± SD: G1: 4.7 ± 2.9 G2: 5.0 ± 2.9 G3: 5.0± 3.2 Incontinence episodes/day, median: G1: 4 G2: 4 G3: 4 Void frequency/day, mean ± SD: G1: 12.4 ± 2.9 G2: 12.1 ± 3.3 G3: 12.3 ± 3.3 Void frequency/day, median: G1: 12 G2: 12 G3: 12 Voided volume, mL, mean ± SD: G1: 165 ± 62 G2: 165 ± 61 G3: 175 ± 68 Voided volume, mL, median: G1: 160 G2: 150 G3: 171 Global assessment of disease, QOL, baseline, (SD): G1: 65 (19) G2: 63 (20) G3: 65 (20) IIQ (QOL)- travel domain, baseline, (SD): G1: 49 (28) G2: 47 (29) G3: 43 (29) UDI (QOL), irritative symptoms, baseline, (SD): G1: 62 (20) G2: 66 (18) G3: 63 (20) | Incontinence episodes/day, mean ± SD: G1: 1.9 ± 2.7 G2: 1.9 ± 3.0 G3: 2.9 ± 3.8 P=0.0137 G1 v G3 P=0.0011 G2 v G3 P=0.5878 G1 v G2 Incontinence episodes/day, mean change±SD G1: 2.9±3.0 G2: 3.2±2.8 G3: 2.1±3.0 Incontinence episodes/day, median G1: 1 G2: 1 G3: 2 Incontinence episodes/day, median change G1: 3 G2: 3 G3: 2 Void frequency/day, mean ± SD: G1: 10.4 ± 3.2 G2: 9.9 ± 3.1 G3: 10.9 ± 3.8 P=0.101 G1 v G3 P= 0.0025 G2 v G3 P=0.276 G1 v G2 Void frequency/day, mean change±SD: G1: −1.9±2.7 G2: −2.2±2.6 G3: −1±1.4 Void frequency/day, median: G1: 10 G2: 10 G3: 10 Void frequency/day, median change: G1: 2 G2: 2 G3: 1 Voided volume, mL, mean ± SD: G1: 198 ± 84 G2: 193 ± 75 G3: 182 ± 84 P=0.0010 G1 v G3 P=0.0017 G2 v G3 P=0.7690 G1 v G2 Voided volume, mL, mean change±SD: G1: 32±55 G2: 29±57 G3: 9±63 Voided volume, mL, median: G1: 188 G2: 189 G3: 165 Voided volume, mL, median change: G1: 24 G2: 29 G3: 5.5 Global assessment of disease, QOL, change, (SD): G1: 30 (30) G2: 33 (28) G3: 21 (31) P=0.0106 G1 v G3 P=0.001 G2 v G3 P=0.1861 G1 v G3 IIQ (QOL)- travel domain, change, (%): G1: 23 (25) G2: 22 (29) G3: 11 (30) P=0.0018 G1 v G3 P=0.0045 G2 v G3 UDI (QOL), irritative symptoms, change, (SD): G1: 25 (26) G2: 28 (26) G3: 18 (24) P=0.0156 G1 v G3 P= 0.0010 G2 v G3 Treatment compliance with assigned dosage regimen: 92%: Frequency decreased to a greater extent for patients with > 14 micturations per day at baseline G1: −2.9/day, p=0.0036 (data for other groups not reported) Adverse effects: Dry mouth, %: G1: 4.1 G2: 7.3 G3: 1.7 P=0.2678 G1 v G3 P=0.0379 G2 v G3 Constipation, (%): G1: 3.3 G2: 5.7 G3: NR Mild systemic adverse effects, n (%): G1: 15 (12.4) G2: 13 (10.6) G3: 6 (5.1) Moderate systemic adverse effects, n (%) G1: 7 (5.8) G2: 13 (10.6) G3: 7 (6.0) Severe systemic adverse effects, n (%) G1: 1 (0.8) G2: 3 (2.4) G3: 1 (0.9) Mild localized application site reactions, n (%): G1: 9 (7.4) G2: 2 (1.6) G3: 5 (4.3) Moderate localized application site reactions, n (%): G1: 17 (14.0) G2: 4 (3.3) G3: 2 (1.7) Severe localized application site reactions, n (%): G1: 6 (5.0) G2: 1 (0.8) G3: 1 (0.9) Treatment discontinuation due to adverse effects, n (%): G1: 13 (10.7) (12 due to application site reactions, 1 due to hot flushes) G2: 2 (1.6) (1 due to fatigue and 1 due to dizziness) G3: NR Postvoid residual>150 mL at end of treatment: G1: 4 G2: 4 G3: 3 No reports of symptomatic urinary retention Withdraw due to AEs: 23 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: − Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Elinoff et al. 2006 Roberts et al. 2006 Country and setting: US; 82 Primary care & Ob-Gyn offices Enrollment period: NR Funding: Pfizer Author industry relationship disclosures: 6 of 6 Pfizer (6) Astellas (1) Novartis (1) | Design: Open-label, single-arm cohort Intervention: Tolterodine ER 4 mg qd for 12 wks Groups: NA N at enrollment: 896 N at follow-up: 758 Age, yrs ± SD: 56 ± 15 Race/ethnicity, N (%): White: 691 (80) Black: 94 (11) Asian: 22 (3) Other: 53 (6) Women, N (%): 708 (82) Parity: NR | Inclusion criteria: • 18+ years old • OAB symptoms for ≥3 mos • ≥ 8 voids/day • 2+ episodes of urgency or UUI in a 3-d period • 3+ on the OAB Bother Rating Scale Exclusion criteria: • Stress, functional, or overflow incontinence • Acute UTI • Clinically significant LUT pathology • Indwelling catheter • Intermittent self-cath • Use of anticholinergics, antimuscarinics for OAB, drugs to trt UUI, potent cytochrome P450 3A4 inhibitors, or investigational drugs | Duration of OAB, yrs ± SD: 6 (8) Trt duration w/study drug, days (SD): 80 (19) Daytime frequency episodes, #/d, mean ± SD: 9.3 ± 2.8 Nocturnal frequency episodes, #/d, mean ± SD: 3.0 ± 1.7 UUI episodes, #/d, mean ± SD: 2.7 ± 3.2 Urgency episodes, #/d, mean ± SD: 5.0 ± 3.8 OAB-q scores Symptom bother: 60.0 Coping: 50.0 Concern: 51.4 Sleep: 44.4 Social Interaction: 84.0 Total HRQL: 55.2 AUA-SI Total: 18 Irritative: 10 Obstructive: 8 Most bothersome symptom, n (%) Daytime frequency: 256 (30) Nocturnal frequency: 241 (28) UUI: 206 (24) Urgency: 154 (18) | Urgency, mean change% (95% CI). wk 12:^^^ −81.3 (−85.7, −73.3) UUI episodes, mean change % (95% CI), wk 12:^^^ −80.0 (−85.7, −69.7) Nighttime frequency, mean change % (95% CI), wk 12:^^^ −40.0 (−44.4, −33.3) Daytime frequency, mean change % (95% CI), wk 12:^^^ −31.6 (−34.6, −28.1) OAB-q scores, Median change from baseline to 12 wks (95% CI): Symptom bother: −37.5 (−37.5, −35.0) Coping: 32.5 (30.0, 35.0) Concern: 34.3 (31.4, 37.1) Sleep: 28.0 (28.0, 32.0) Social Interaction: 12.0 (12.0 to 16.0) Total HRQL: 28.9 (27.2 to 31.2) [underlined: AUA-SI, Median change from baseline to 12 wks (95% CI)] ^*^Total: −9 (−9 to −8) ^*^Irritative: −5 (−5 to −5) ^*^Obstructive: −4 (−4 to −3) ^*^: p<0.001 Urgency, mean change, wk 12 % (95% CI): −75.0 (−80.0, −71.4) Change from baseline to wk 12, UUI episodes, mean % (95% CI): −86.1(−80.0, −71.4) Nighttime frequency, mean change % (95% CI): −37.5 (−40.0, −33.3) Daytime frequency, mean change, wk 12 % (95% CI): −29.0 (−31.0, −27.3) All-cause AE: 51% Discontinued treatment, n %: 15 (7) Trt-related AE: 23% Dry mouth, %: 10.0 Constipation, %: 3.7% Headache, %: 3.0% UTI, %: 2.7% | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: + Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Garely et al., 2007^*^ Mallett et al., 2007^^^ Country and setting: US, multicenter (207 sites) Enrollment period: NR Funding: Astellas Pharma US Glaxo-SmithKline Author industry relationship disclosures: 4 of 4^*^ Astellas (4) Pfizer (1) Novartis (1) 4 of 4^^^ Astellas (3) GlaxoSmthKline (2) Novartis (1) Watson (1) Yamanouchi (1) | Design: Prospective case series Intervention: Solifenacin qd (started on 5 mg/d; option of increasing to 10 mg/d at week 4; option to maintain 10 mg dose or decrease to 5 mg at wk 8); for 12 weeks of treatment 10 mg dose, n (%): 4 wks: G1: 55% 8 wks: G1: 59% (8% went back to 5mg; 19% increased to 10 mg) Groups: G1: Urge incontinence as most bothersome symptom G2: Black participants G3: Full study population N at enrollment: G1:582 G2: 274 G3: 2205 Age, mean yrs ± SD: G1: 60.9 ± 13.1 G2: 54.7 ± 13.6 G3: 59.7 ± 14.4 Race/ethnicity, n (%): White: G1: 493 (84.7) G3: 1761 (79.9) African American: G1: 62 (10.7%) G3: 274 (12.4%) Other: G1: 27 (4.6%) G3: 170 (7.7%) Women, n (%): G1: 536 (92.1) G2: 213 (77.7) G3: 1813 (82.2) Weight (lbs), mean ± SD (range): G2: 198 ± 51.6 (100–400) G3: 182.2 ± 47.0 (80–413) | Inclusion criteria: •-Age ≥ 18 •Symptoms of OAB for ≥ 3 mos •Ambulatory •Able to use the toilet without difficulty •Urgency, UUI, frequency or nocturia ≥ 3 mos Exclusion criteria: •Previous use of solifenacin | UUI, n (%): G1: 582 (100%) G2: NR G3: 1596 (71.9%) Urgency, n (%): G1: 534 (91.8) G2: NR G3: 2007 (91.0) Frequency, n (%): G1: 488 (83.8) G2: NR G3: 1969 (89.3) Nocturia, n (%): G1: 438 (75.3) G2: NR G3: 1792 (81.3) Most bothersome OAB symptom Urgency, n (%): G2: 48 (17.5) G3: 508 (23.0) UUI, n (%): G1: 582 (100) G2: 63 (23.0) G3: 602 (27.3) Frequency, n (%): G2: 106 (38.7) G3: 619 (28.1) Nocturia, n (%): G2: 34 (12.4) G3: 337 (15.3) None specified, n (%): G2: 23 (8.4) G3: 139 (6.3) OAB for 3 mos -1 yr, n (%): G1: 57 (9.8) G3: 349 (15.8%) OAB for 1–5 yrs, n (%): G1: 294 (50.5) G3: 1124 (51.0) OAB for >5 yrs: G1: 231 (39.7) G3: 732 (33.2) Perception of bladder condition scale (mean): G1: 4.6 G2: 4.2 G3: 4.4 Symptom severity, mean VAS: Urinary urgency: G1: 72.3 G2: 70.8 G3: 68.7 UUI: G1: 78.5 G2: 70.8 G3: 64.1 Frequency: G1: 65.7 G2: 70.8 G3: 70.6 Nocturia: G1: 57.9 G2: 66.5 G3: 65.2 OAB-q, symptom severity, mean ± SE: G1: 63.1 ± 0.84 G2: 59.4 (NR) G3: 56.9 (NR) OAB-q, coping, mean ± SE: G1: 48.9 ± 1.18 G2: 46.5 (NR) G3: 53.1 (NR) OAB-q, concern, mean ±SE: G1: 43.1 ± 1.12 G2: 46.6 (NR) G3: 50.8 (NR) OAB-q, sleep, mean ± SE: G1: 55.2 ± 1.22 G2: 43.8 (NR) G3: 49.2 (NR) OAB-q, social, mean ± SE: G1: 73.6 ± 1.14 G2: 68.9 (NR) G3: 76.0 (NR) OAB-q, HRQoL, mean ± SE: G1: 53.4 ± 1.01 G2: 50.5 (NR) G3: 56.3 (NR) | Patient perception of bladder condition scale, 4 wks, mean: G1: 3.3^*^ G2: 3.1^*^ G3: 3.3^*^ Patient Perception of Bladder Condition Scale, 8 wks, mean: G1: 3.0^*^ G2: 2.7^*^ G3: 2.9^*^ Patient Perception of Bladder Condition Scale, 12 wks or early termination, mean: G1: 2.9^*^ G2: 2.6^*^ G3: 2.9^*^ Symptom severity, mean VAS, wk 4: Urinary urgency: G1: 40.9 G2: 39.7 G3: 40.6 UUI: G1: 36.9 G2: 29.9 G3: 32.8 Frequency: G1: 34.5 G2: 39.3 G3: 39.9 Nocturia: G1: 30.4 G2: 35.4 G3: 38.2 Symptom severity, mean VAS, wk 8: Urinary urgency: G1: 31.1 G2: 29.4 G3: 30.0 UUI: G1: 28.9 G2: 22.1 G3: 24.5 Frequency: G1: 24.9 G2: 27.0 G3: 28.6 Nocturia: G1: 25.4 G2: 36.4 G3: 29.0 Symptom severity, mean VAS, wk 12 (or early termination): Urinary urgency: G1: 27.5 G2: 25.3 G3: 28.0 UUI: G1: 24.3 G2: 20.0 G3: 22.7 Frequency: G1: 21.6 G2: 24.5 G3: 27.4 Nocturia: G1: 22.0 G2: 21.4 G3: 27.2 Symptom severity, VAS, mean change from baseline (95% CI): Urinary urgency^*^: G1: −43.1 (−45.8, −40.4) G2: −43.0 (−47.6, −38.5) G3: −39.5 (−41.0, −38.1) UUI^*^: G1: −51.7 (−54.5, −49.0) G2: −42.3 (−47.8, −36.8) G3: −40.1 (−41.8, −38.4) Frequency^*^: G1: −42.0 (−45.0, −39.0) G2: −44.2 (−48.8, −39.6) G3: −41.8 (−43.3, −40.3) Nocturia^*^: G1: −34.4 (−37.3, −31.5) G2: −42.6 (−47.5, −37.8) G3: −36.9 (−38.4, −35.4) OAB-q, symptom severity, mean change (± SE or 95% CI)^*^: G1: −35.9 ± 1.08 G2: −33.6 (−37.0, −30.3) G3: −29.6 (−30.7, −28.6) OAB-q, coping, mean change (± SE or 95% CI)^*^: G1: 32.5 ± 1.16 G2: 32.9 (29.3, 36.6) G3: 27.4 (26.2, 28.5) OAB-q, concern, mean change (± SE or 95% CI)^*^: G1: 37.0 ± 1.21 G2: 34.0 (30.4, 37.6) G3: 29.6 (28.4, 30.8) OAB-q, sleep, mean change (± SE or 95% CI)^*^: G1: 26.0 ± 1.19 G2: 33.8 (29.7, 37.9) G3: 27.3 (26.1, 28.5) OAB-q, social, mean change ± SE (95% CI)*: G1: 17.7 ± 1.03 G2: 20.1 (16.7, 23.5) G3: 14.7 (13.7, 15.6) OAB-q, HRQoL, mean change (± SE or 95% CI)*: G1: 29.6 ± 1.02 G2: 30.8 (27.5, 34.1) G3: 25.4 (24.4, 26.4) Side effects, n (%): G1: 357 (61.3) G2: 128 (46.4) G3: 1321 (59.4) Dry mouth, n (%): G1: 104 (17.9) G2: 36 (13.0) G3: 477 (21.4) Constipation, n (%): G1: 85 (14.6) G2: 19 (6.9) G3: 295 (13.3) Nausea, n (%): G1: NR G2: 7 (2.5) G3: 39 (1.8) Headache, n (%): G1: 21 (3.6) G2: 9 (3.3) G3: 76 (3.4) Blurred vision, n (%): G1: 20 (3.4) G2: 7 (2.5) G3: 57 (2.6) Upper respiratory tract infection, n (%): G1: 27 (4.6) G2: 7 (2.5) G3: 69 (3.10) UTI, n (%) G1: 21 (3.6%) G2: NR G3: NR Rash, n (%): G1: NR G2: 6 (2.2) G3: 22 (0.99) Nasopharyngitis, n (%) G1: 13 (2.2%) G2: NR G3: NR Cough, n (%) G1: 12 (2.1%) G2: NR G3: NR Withdrew, n (%): G1: NR G2: 21 (7.6) G3: 216 (9.7) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: − Loss to followup: NR Drop-out rates: + Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Giannitsas et al., 2004 Country and setting: Greece, Specialty treatment center Enrollment period: NR Funding: NR Author industry relationship disclosures: NR | Design: Randomized for which drug to receive first two-way crossover, table of random numbers Intervention: Oxybutynin 15 mg tid vs Tolterodine 4mg bid; 6 weeks treatment with 3–4 weeks washout Groups: G1: Oxybutynin 15 mg tid G2: Tolterodine 4mg bid Stratified by UDS findings: a: high volume (> 250mL); low pressure (< 25cmH_2_O) b: high volume (≥ 250mL); high pressure (> 25cmH_2_O) C: low volume (< 250mL); low pressure (< 25cmH_2_O) d: low volume (< 250mL); high pressure (> 25cmH_2_O) N at enrollment: Total: 128 N at follow-up: Total: 107 Ga: 6 Gb: 25 Gc: 36 Gd: 40 Women, %: 100 Age, mean ± SD: Total: 56 ±16.3 Ga: 53 ± 17.2 Gb: 57 ± 16.2 Gc: 57 ± 16.3 Gd: 54 ± 16.6 Weight (kg), mean ± SD: Total: 63 ± 5.6 Ga: 63 ± 5.6 Gb: 70 ± 9.1 Gc: 67 ± 8.8 Gd: 69 ± 7.5 | Inclusion criteria: • Age ≥ 18 • DO on urodynamics Exclusion criteria: • Symptomatic or recurrent UTI • BOO • Neurologic disease • History of previous pelvic surgery • Narrow angle glaucoma • SUI • History of anticholinergic side effects • Interstitial cystitis • Child-bearing age without BC | Voids/day, mean ± SD: Total: 8.5 ± 2.63 Ga: 7.2 ± NR Gb: 8.0 ± 2.40 Gc: 8.3 ± 2.31 Gd: 9.3 ± 2.91 Volume (mL)/day, mean ± SD: Total: 1568.5 ± 398.64 Ga: 1756 ± NR Gb: 1594.6 ± 326.12 Gc: 1678.8 ± 402.15 Gd: 1420.5 ± 384.96 Voided volume (mL), mean ± SD: Total: 196.1 ± 60.19 Ga: 253 ± NR Gb: 213.5 ± 53.57 Gc: 209.8 ± 57.43 Gd: 163.4 ± 51.97 Bladder volume (mL), first desire void, mean ± SD: Total: 105.6 ± 39.38 Ga: 109 ± NR Gb: 128.0 ± 41.78 Gc: 94.3± 35.40 Gd: 101.1 ± 38.14 Bladder volume (mL), first contraction, mean ± SD: Total: 172 ± 98.4 Ga: 258 ± NR Gb: 303.3 ± 60.51 Gc: 111.9 ± 48.11 Gd: 124.4 ± 56.66 Pressure (cmH_2_0), first contraction, mean ± SD: Total: 34.8 ± 21.97 Ga: 17.4 ± NR Gb: 37.7 ± 14.03 Gc: 18.5 ± 4.60 Gd: 50.3 ± 25.14 Overactivity index, mean ± SD: Total: 36.8 ± 31.36 Ga: 15.3 ± NR Gb: 24.8 ± 19.66 Gc: 26.3 ± 16.14 Gd: 57.0 ± 38.85 Cystometric capacity (mL), mean ± SD: Total: 362.8 ± 119.10 Ga: 403 ± NR Gb: 410.0 ± 97.78 Gc: 357.6 ± 127.52 Gd: 331.4 ± 114.17 | Voids/day, mean ± SD: G1: 7.7 ± 1.87 G2: 7.6 ± 2.18 G1a: 6.1 ± NR G2a: 6.3 ± NR G1b: 7.3 ± 1.69 G2b: 7.0 ± 1.87 G1c: 7.5 ± 1.41 G2c: 7.2 ± 1.58 G1d: 8.3 ± 2.23 G2d: 8.4 ± 2.53 Volume (mL)/day, mean ± SD: G1: 1764.4 ± 333.03 G2: 1670.7 ± 338.6 G1a: 1862 ± NR G2a: 1720 ± NR G1b: 1715.6 ± 292.54 G2b: 1665.8 ± 251.19 G1c: 1847.9 ± 333.81 G2c: 1808.1 ± 317.59 G1d: 1694.7 ± 331.33 G2d: 1550.3 ± 373.65 Voided volume (mL), mean ± SD: G1: 239.9 ± 64.98 G2: 236.7 ± 63.03 G1a: 321 ± NR G2a: 286 ± NR G1b: 243.3 ± 59.56 G2b: 248.3 ± 53.91 G1c: 252.9 ± 55.75 G2c: 258.6 ± 60.63 G1d: 217.6 ± 67.07 G2d: 203.1 ± 55.43 Bladder volume (mL), first desire void, mean ± SD: G1: 129.0 ± 30.14 G2: 117.9 ± 27.62 G1a: 144 ± NR G2a: 140 ± NR G1b: 153.5 ± 25.72 G2b: 132.0 ± 31.01 G1c: 120.8 ± 25.07 G2c: 113.2 ± 23.16 G1d: 119.4 ± 29.43 G2d: 110.1 ± 26.15 G1/BL: P < 0.05 G2/BL: P < 0.05 Bladder volume (mL), first contraction, mean ± SD: G1: 212.9 ± 106.10 G2: 206.9 ± 103.56 G1a: 382 ± NR G2a: 364 ± NR G1b: 355.28 ± 74.79 G1c: 142.4 ± 43.51 G2c: 144.6 ± 48.43 G1d: 173.3 ± 57.37 G2d: 162.7 ± 53.87 G1d/BL: P < 0.01 G2d/BL: P < 0.01 Pressure (cmH_2_0), first contraction, mean ± SD: G1: 30.9 ± 22.63 G2: 30.9 ± 19.01 G1a: 14.0 ± NR G2a: 17.4 ± NR G1b: 35.6 ± 12.86 G2b: 29.6 ± 13.56 Pressure (cmH_2_0), first contraction, mean ± SD: G1c: 17.2 ± 6.80 G2c: 17.9 ± 6.69 G1d: 42.9 ± 28.91 G2d: 44.1 ± 20.75 Overactivity index, mean ± SD: G1: 24.4 ± 22.61 G2: 24.7 ± 23.46 G1a: 7.0 ± NR G2a: 9.5 ± NR G1b: 14.1 ± 12.09 G2b: 14.1 ± 12.71 G1c: 18.3 ± 15.89 G2c: 16.9 ± 16.84 G1d: 38.9 ± 26.50 G2d: 40.7 ± 26.58 Cystometric capacity (mL), mean ± SD: G1: 419.3 ± 120.86 G2: 415.63 ± 114.06 G1a: 465 ± NR G2a: 453 ± NR G1b: 449.6 ± 106.23 G2b: 459.4 ± 101.17 G1c: 409.9 ± 130.22 G2c: 411.05 ± 132.49 G1d: 401.8 ± 118.34 G2d: 386.7 ± 96.53 Dry mouth, n (%): G1: 52 (40.6) G2: 20 (15.6) Constipation, n (%): G1: 11 (10.3) G2: 3 (2.8) Discontinued due to AEs, n: Dry mouth: 12 Palpitations: 1 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: + Masking: NA Pt selection criteria: + Loss to followup: ++ Drop-out rates: - Power calculation: - Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: - Measurement methods: + Measurement reliability: + Intervention description: +
Author: Gleason et al. 1999 Country and setting: US, Community Enrollment period: NR 12 week follow up Funding: Alza Corporation Author industry relationship disclosures: NR | Design: Multicenter Open label Single treatment Intervention: Oxybutynin ER Groups: G1: Oxybutynin ER 5–30 mg/day (dose adjustment period) N at enrollment: G1: 256 N at follow-up: G1: 219 37 missing data 20 from AEs 4 dc’d lack of effectiveness, included in analysis Age, yrs ± SD: NR 38.8% were 65+ Race/ethnicity, mean (%): white: G1: 235 (91.8) Women, N (%): G1: 234 (91.4) | Inclusion criteria: • ≥ adult men and women • Idiopathic urge incontinence • Mixed incontinence with clinically significant urge component Exclusion criteria: • Uncontrolled medical condition • PVR > 100 ml • Significant bacteriuria • Significant pyuria | UUI episodes/week, mean ± SD: G1: 18.8 ± 1.2 Total incontinent episodes/week, mean ± SD: G1: 22.2 ± 1.3 Voids/week, mean ± SD: G1: 81.1 ± 1.8 PVR, ml, mean ± SD: G1: 17.4 ± 1.3 Voided volume, ml, ± SD: G1: 121 ± 79.1 | UUI episodes/week, mean ± SD: G1: 2.8 ± 0.6 P<0.001 Total incontinent episodes/week, mean ± SD: G1: 4.0 ± 0.7 P<0.001 Voids/week, mean ± SD: G1: 66.8 ± 1.4 Reduction Voids/week, mean ± SD: G1: 14.3 ± 1.3 95%CI: 11.7–16.8 PVR, ml, mean ± SD: G1: 21.0 ± 2.2 P = NR Voided volume, ml, ± SD: G1: 113.4 ± 84.6 P = NR Participants free UUI episodes, %: 55.7 Dry Mouth, n (%): G1: 128 (58.6) Discontinuation d/t AE, n (%): 20 (7.8) Nausea (%): 2.3 Dry Mouth (%): 1.6 Somnolence (%): 1.2 Urinary retention, n (%): 2 (0.8) Increased PVR, n, (%): 1 (0.4) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: + Drop-out rates: ++ Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Hill et al., 2007 [See evidence table for Haab et al., 2006] Country and setting: France, Denmark, Sweden, Australia, Canada, US, Multicenter Enrollment period: NR Funding: Novartis Pharma AG (educational grant) Author industry relationship disclosures: NR | Design: 2-yr, non-comparative, open-label extension study Intervention: Darifenacin following 2 feeder studies of darifenacin 3.75/7.5/15 mg qd or placebo x 12 wks Groups: NA N at enrollment: 214 N at follow-up (%): 137 (64.0) Patient years of exposure: 308 Women, n (%): 172 (80.4) Age, n (%): 65–74 years: 166 (77.6) 75–89 years: 48 (22.4) Race/ethnicity: NR Menopausal, n (%): 13 (6.1) | Inclusion criteria: • Age ≥ 65 • Successful completion of one of 2 previous, 12-wk feeder studies with no major protocol violation Exclusion criteria: NR | Urgency episodes/day, median: 8.1 Urgency severity, median VAS score: 51.8 Incontinence episodes/week, median: 18.7 Voids/day, median: 10.1 Voided volume (mL), median: 156 Concomitant drug treatment, n (%): 210 (98.1) | Urgency episodes/day, median change (median % change): −3.7 (−52.0) P < 0.05 Urgency severity, VAS score, median change (median % change): −12.6 (−23.3) P < 0.05 Incontinence episodes/week, median change (median % change): −11.0 (−83.7) P < 0.05 Significant leaks/week, median change (median % change): −4.9 (−100.0) P < 0.05 Incontinence episodes, responders, % reduction, %: ≥ 50%: 74.1 ≥ 70%: 60.0 ≥ 90%: 44.4 Voids/day, median change (median % change): −1.2 (−12.4) P < 0.05 Normalization of voiding frequency (< 8 voids/day) after darifenacin treatment, %: 3 months: 34 2 years: 33.8 Nocturia episodes/week, median change (median % change): −1.4 (−10.9) G1/BL: P < 0.05 Increased dose to 15 mg at 2 wks and maintained, n (%): 110 (51.4) Remained on 7.5 mg dose, n (%): 55 (25.7) Had dose adjusted at other times, n (%): 49 (22.9) Compliance, ≥ 80% of doses, n (%): 214 (84) Voided volume (mL), median change (median % change): 11.1 (6.3) Dry mouth, n (%): 50 (23.4) Constipation, n (%): 48 (22.4) CVD, %: 1.4 Peripheral/CNS, %: 3.3 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: + Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Jacquetin and Wyndaele, 2001 Country and setting: France (22 centers) and Belgium (10 centers) Enrollment period: NR Funding: Pharmacia Author industry relationship disclosures: NR | Design: Double-blind, placebo-controlled, parallel-group, multicenter phase III study w/2-wk washout period Intervention: Tolterodine vs placebo for 4 weeks Groups: G1: Tolterodine 2mg bid G2: Tolterodine 1 mg bid G3: placebo (frequency NR) N at enrollment: NR N at follow-up: G1: 103 G2: 97 G3: 51 Women, n (%): G1: 84 (82) G2: 74 (76) G3: 41 (80) Age, mean (range): G1: 58 (21–88) G2: 53 (18–85) G3: 56 (19–89) Race/ethnicity: NR BMI, kg/m^2^ (range): G1: 26.4 (17.7–39.7) G2: 25.5 (16.7–46.3) G3: 24.8 (17.6–36.9) | Inclusion criteria: • Age ≥ 18 • UDS-verified detrusor overactivity • ≥ 1 UUI episode/day • ≥ 8 voids/day Exclusion criteria: • SI • Hepatic or renal dz • +UTI or recurrent UTIs • Interstitial cystitis • Hematuria • Clinically significant voiding difficulty • Pts receiving bladder training, electrostimulation therapy • Indwelling catheter • Intermittent cath • Pregnant or nursing • Women of childbearing age w/o reliable contraception | UUI, n (%) G1: 75 (73) G2: 75 (77) G3: 39 (76) UUI episodes/day, mean (range): G1: 3.2 (0.1–24.0) G2: 2.7 (0.1–24.0) G3: 2.4 (0.1–8.4) Voids/day, mean (range): G1: 10.8 (6.2–34.7) G2: 10.7 (4.9–26.4) G3: 11.7 (6.3–26.3) ≥ 8 voids/day, n (%): G1: 96 (93) G2: 89 (92) G3: 49 (96) Urinary symptoms > 5 years, n (%): G1: 46 (45) G2: 42 (43) G3: 17 (33) Previous lower urinary tract surgery, n (%): G1: 36 (35) G2: 29 (30) G3: 16 (31) Previous drug therapy for OAB, n (%): G1: 66 (64) G2: 59 (61) G3: 36 (71) Previous poor efficacy response, n (%): G1: 50 (76) G2: 45 (76) G3: 26 (72) Voided volume (mL), mean (range): G1: 158 (43–382) G2: 150 (46–320) G3: 148 (23–284) | UUI episodes/day, mean change ± SD: G1: −1.3 ± 1.8 G2: −1.1 ± 2.2 G3: −0.4 ± 1.9 G1/G3: P = 0.0089 G2/G3: P = 0.045 Voids/day, mean change ± SD: G1: −1.4 ± 4.3 G2: −1.4 ± 2.8 G3: −1.2 ± 2.7 G1/G3: P = NS G2/G3: P = NS Good efficacy response in current study, previous poor efficacy response, n/N (%) G1: 20/39 (51) G2: 18/37 (49) G3: 7/19 (37) G1/G3: P = NS G2/G3: P = NS Voided volume (mL), mean change ± SD: G1: 19 ± 46 G2: 20 ± 42 G3: 7 ± 40 G1/G3: P = 0.056 G2/G3: P = 0.055 Dry mouth, n (%): G1: 35 (34) G2: 20 (21) G3: 3 (6) G1/G2: P < 0.05 G1/G3: P < 0.05 G2/G3: P < 0.05 Abdominal pain, n (%): G1: 4 (4) G2: 6 (6) G3: 2 (4) Constipation, n (%): G1: 2 (2) G2: 4 (4) G3: 2 (4) Headache, n (%): G1: 3 (3) G2: 3 (3) G3: 2 (4) Total AEs reported, n: G1: 84 G2: 78 G3: 26 Any AE, n (%): G1: 55 (53) G2: 39 (40) G3: 16 (31) G1/G3: P < 0.05 Discontinued due to AEs, n (%):* G1: 2 (2) G2: 3 (3) G3: 1 (2) | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: − Masking: + Pt selection criteria: + Loss to followup: NR Drop-out rates: ++ Power calculation: + Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Koonings et al., 1991 Country and setting: US Enrollment period: January 1986 to October 1987 Funding: NR Author industry relationship disclosures: NR | Design: Cohort Intervention: Oxybutynin chloride 5 mg tid × 4 wks Groups: NA N at enrollment: 126 N at follow-up: 114 Women, %: 100 Age, mean (range): 39 (21–74) Race/ethnicity: NR Menopausal, n: 44 Parity, mean (range): 2 (0–12) | Inclusion criteria: • Confirmed diagnosis of detrusor instability • Uninhibited detrusor contraction > 15 cm H_2_O on standing provocative urethra cystometry Exclusion criteria: • Urethritis (on urethroscopy) • Cystitis (on cystoscopy) • Neurologic findings on screening test of S2–S4 lower voiding center • MUI • Glaucoma | Uninhibited detrusor contraction starting prior to urethral pressure change, n (%): 73 (64%) Urethral pressure drop (≥ 20 cmH_2_O) prior to detrusor contraction, n (%): 41 (6) | Good response, n (%): 66 (58) Poor response, n (%): 48 (42) Response, women with uninhibited detrusor contraction starting prior to urethral pressure, n (%): Good: 61 (81) Poor: 5 (12) P < 0.01 Response, women with urethral pressure drop (≥ 20 cmH_2_O) prior to detrusor contraction, n (%): Good: 12 (16) Poor: 36 (88) P < 0.01 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: ++ Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Kreder et al., 2003 Country and setting: US and Canada, Community Enrollment period: NR 16 week follow up Funding: Pharmacia Corporation Author industry relationship disclosures: NR | Design: Subgroup analysis of multicenter, single blind cohort Intervention: Tolterodine 1–2 mg bid Groups: G1: MUI with primary urge G2: UUI N at enrollment: G1: 171 G2: 552 N at follow-up: G1: 170 G2: 551 Women, n (%): G1: 165 (96.5) G2: 464 (84) Age, median (range): G1: 62 (21, 88) G2: 65 (20, 88) Race/ethnicity: NR | Inclusion criteria: • Age ≥ 65 • History, PE, UDS consistent with urge incontinence • ≥ 4 episodes UI on 5 day voiding diary • ≥ 8 voids/day • Either urgency or ≥ 1 UI episodes/day Exclusion criteria: • MUI with predominate stress component • Contraindications to antimuscarinic therapy • Hepatic/renal disease • Symptomatic or recurrent UTI • Hematuria • IC • Voiding difficulty with risk of retention • Concurrent bladder training • Electrostimulation therapy • Indwelling catheter • CIC • Women with reproduction potential • Pregnant/nursing • Concomitant anticholinergic meds/treatment | Incontinence episodes/day, median (range): G1: 3 (1, 19) G2: 3 (1, 15) ≥ 2 nocturia episodes/day, n (%): G1: 100 (58.5) G2: 334 (60.5) Using pads, n (%): G1: 122 (71) G2: 342 (62) Voided volume (mL), median (range): G1: 169 (62, 506) G2: 164 (31, 524) Duration of symptoms > 5 years, n (%): G1: 91 (53) G2: 259 (47) Previous drug therapy for OAB, n (%): G1: 85 (50) G2: 275 (50) | Incontinence episodes/day, median % change: G1: −67 G2: −75 P = NS Cure rate, dryness, n (%): G1: 66 (39) G2: 243 (44) P = NS Voids/day, median % change: G1: −15 G2: −17 P = NS ≤ 8 voids/day dryness, n (%): G1: 40 (23.5) G2: 130 (24) P = NS Nocturia episodes/day, median % change: G1: −50 G2: −33 P = NS ≤ 2 nocturnal voiding episodes/day, n (%): G1: 83 (83) G2: 254 (76) P = NS Achieved no pad usage, n (%): G1: 26 (21) G2: 93 (27) P = NS Voided volume (mL), median change (range): G1: 26.5 (−261, 195) G2: 27 (−345, 389) G1/BL: P < 0.001 G2/BL: P < 0.001 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: − Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Landis et al., 2004 [See evidence table for van Kerrebroeck et al., 2001] Country and setting: Multinational, Community Enrollment period: NR 12 weeks Funding: Pharmacia Author industry relationship disclosures: 2 of 4 ALZA (1) Bristol-Myers Squibb (1) Pharmacia (2) | Design: RCT Intervention: Tolterodine ER vs placebo 1 week run-in period with 12 weeks treatment Groups: G1: Tolterodine ER 4 mg daily G2: placebo Stratified: a: 5–20 UUI episodes/week b: ≥ 21 UUI episodes/week N at enrollment: G1: 492 G1a: 321 G1b: 171 G2: 494 G2a: 284 G2b: 210 N at follow-up: G1a: 321 G1b: 171 G2a: 284 G2b: 210 Women, N (%): G1a: 262 (81.6) G1b: 143 (83.6) G2a: 223 (78.5) G2b: 178 (84.8) Age, mean ± SD: G1a: 60.86 ± 14.45 G1b: 60.04 ± 14.10 G2a: 60.61 ± 13.59 G2b: 61.84 ± 13.85 Race/ethnicity: NR | Inclusion criteria: • Age ≥ 18 • ≥ 5 UUI episodes/week • ≥ 8 voids/day • Symptoms of OAB × 5 months Exclusion criteria: NR | UUI episodes/week, median (range): G1a: 11 (5–20) G1b: 34 (21–168) G2a: 11 (5–20) G2b: 31.5 (21–168) Voids/day, median (range): G1a: 9.57 (2.57–34.85) G1b: 10.71 (2.28–51.28) G2a: 10.28 (2.28–28.42) G2b: 11.14 (2–37.42) Voided volume (mL), median (range): G1a:142.72 (36.19–338) G1b: 135.12 (51.45–270.52) G2a: 136.25 (32.51–237.5) G2b: 126.94 (21.16–373.46) Number prior Tx for OAB, n (%): G1a: 162 (50.6) G1b: 100 (58.5) G2a: 139 (49.1) G2b: 117 (55.7) Number prior Tx for OAB w/good efficacy, n (%): G1a: 85 (52.8) G1b: 63 (63.0) G2a: 84 (60.4) G2b: 68 (58.6) | UUI episodes/week, median % change: G1a: −71.42 G1b: −67.56 G2a: −38.46 G2b: −29.81 G1a/G2a: P = 0.0264 G1b/G2b: P = 0.0221 Voids/day, median change: G1a: −1.22 G1b: −1.9 G2a: −0.85 G2b: −0.4 G1a/G2a: P < 0.04 G1b/G2b: P < 0.02 Voided volume (mL), median change: G1a: 24.0 G1b: 27.0 G2a: 4.0 G2b: 2.9 G1a/G2a: P < 0.0001 G1a/G2a: P < 0.0001 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: − Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Layton et al. 2001 Country and setting: England; Community Enrollment period: November 1998 to May 1999 Funding: Pharmacia Upjohn Author industry relationship disclosures: NR | Design: Prospective observational cohort Intervention: Tolterodine prescription event monitoring in UK Groups: NA N at enrollment: 35,295 had commenced treatment 26,991 green forms mailed out 14,526 returned forms Response rate: 53.8% Age, yrs ± SD: 62.7 ± 16.4 Women, N (%): 9965 (68.6) Parity: NR | Inclusion criteria: • Patients prescribed tolterodine in general practice in UK Exclusion criteria: • None | | Dry mouth, n: 250 Unspecified adverse effects, n: 168 Headache, n: 123 Constipation, n: 78 General malaise, n: 78 Hallucinations, n: 23 Palpitations/tachycardia, n: 42 Other cardiac arrhythmias, n: 29 Chest pains, n: 87 | Quality: Overall quality score: good INTERNAL VALIDITY: good Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: NA Drop-out rates: NA Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: NR Baseline characteristics: + Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: −
Author: Lee et al., 2002 Country and setting: South Korea, University Enrollment period: NR Funding: Pharmacia Corp Author industry relationship disclosures: NR | Design: RCT Intervention: Tolterodine 2mg bid vs Oxybutynin 5mg bid Groups: G1: Tolterodine 2mg bid G2: Oxybutynin 5mg bid N at enrollment: G1: 112 G2: 116 N at follow-up: G1: 97 G2: 90 Women, n (%): G1: 84 (74) G2: 92 (79) Age, mean (range): G1: 52 (27, 82) G2: 52 (20, 86) Race/ethnicity (%): Asian: G1: 100 G2: 100 BMI, kg/m^2^ (range): G1: 23 (17, 32.5) G2: 23.5 (16, 38) Previous drug therapy: N (%) G1: 36 (32) G2: 26 (22) | Inclusion criteria: • Age ≥ 18 • OAB symptoms > 6 mos • ≥ 8 voids/day, with or without incontinence (measured by diary) Exclusion criteria: • SUI • Women not using reliable contraception • Pregnant or nursing • Prior treatment with anticholinergic < 2 wks • Renal or hepatic disease • Narrow angle glaucoma • Urinary retention • Gastric retention • Hypersensitivity to drugs • UTI • IC • Hematuria • BOO • Concomitant bladder training, e-stim treatment • Indwelling catheter • CIC • Concomitant treatment for OAB ≤ 2 mos | Incontinence episodes/day, mean (range): G1: 2.6 (0.3, 9.3) G2: 2.4 (3.0, 14.7) Patients with incontinence episodes, n (%): G1: 46 (41) G2: 42 (36) Voids/day, mean (range): G1: 12.2 (8.0, 23.7) G2: 12.4 (7.7, 29.7) | Incontinence episodes/day, mean change ± SD (% change): G1: −2.2 ± 2.3 (−85) G2: −1.4 ± 1.8 (−58) G1/BL: P = 0.0001 G1/BL: P = 0.0001 G1/G2: P = 0.10 Voids/day, mean change ± SD (% change): G1: −2.6 ± 2.9 (−21) G2: −1.8 ± 4.2 (−15) G1/BL: P = 0.0001 G1/BL: P = 0.0001 G1/G2: P = 0.14 Benefit of Tx, %: G1: 45 G2: 46 G1/G2: P = NS Patients reporting adverse events, n (%): G1: 62 (55) G2: 94 (82) Discontinued due to AEs, n (%): G1: 11 G2: 18 Dry mouth, n (%): G1: 39 (35) G2: 72 (63) G1/G2: P = 0.001 Dry mouth, mild, n (%): G1: 29 (26) G2: 40 (35) Dry mouth, moderate, n (%): G1: 9 (8) G2: 26 (23) Dry mouth, severe, n (%): G1: 1 (1) G2: 6 (5) Voiding disorder, n (%): G1: 10 (9) G2: 16 (14) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: + Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Malone-Lee et al., 2003 Country and setting: UK, Hospital Enrollment period: 1993–1999 Funding: NR Author industry relationship disclosures: NR | Design: Prospective observational Intervention: Oxybutynin 2.5mg bid and bladder retraining Groups: G1: urinary frequency and urgency w/detrusor instability G2: urinary frequency and urgency w/o detrusor instability N at enrollment: G1: 266 G2: 86 N at follow-up: Total: 347 G1: NR G2: NR Age, mean (range): G1: 54.8 (20, 90) G2: 51.8 (21, 88) Race/ethnicity: NR | Inclusion criteria: • Women • Age ≥ 18 • ≥ 8 voids/day Exclusion criteria: • Neurological disease • Significant stress incontinence • Symptomatic UTI • Interstitial cystitis | Incontinence episodes/day, median (95% CI): G1: 2 (0, 7) G2: 2 (0, 6.3) Voids/day median (95% CI): G1: 14 (8, 24) G2: 12 (8, 22) | Incontinence episodes/day, median change (95% CI): G1: 0 (2, 6) G2: 0 (2, 6) G1/G2: P = 0.73 Voids/day, median change (95% CI): G1: −5 (1.9–14) G2: −5 (1–12.3) G1/G2: P = 0.61 Dry mouth, n (%): G1: 219 (84) G2: 69 (70) Constipation, n (%): G1: 84 (32) G2: 19 (22) Heartburn, n (%): G1: 71 (27) G2: 20 (23) Dry skin, n (%): G1: 46 (18) G2: 4 (5) G1/G2: P = 0.01 Headache, n (%): G1: 25 (10) G2: 3 (3.5) Dry eyes, n (%): G1: 12 (5) G2: 1 (1) | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: ++ Drop-out rates: NR Power calculation: − Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: + Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Michel et al., 2002 Country and setting: Germany, Community Enrollment period: NR 12 week follow up Funding: Pharmacia GmbH Author industry relationship disclosures: 1 of 4 Pharmacia(1) Sanofi-Synthelabo(1) | Design: Open-label observational post-marketing surveillance Intervention: Tolterodine Groups: Tolterodine Median dose: 2 mg daily Dose (mg), mean ± SD: 3.81 ± 1.16 N at enrollment: 2,250 N at follow-up: 1,979 Women, n (%): 1,730 (76.9) Age, mean ± SD: 61.1 ± 13.8 Race/ethnicity: NR BMI, kg/m^2^ ± SD: 73.2 ± 11.3 | Inclusion criteria: • Physician medical judgement Exclusion criteria: NR | Urgency episodes/day, mean ± SD: 8.4 ± 5.1 Incontinence episodes/day, mean ± SD: 3.4 ± 4.2 Voids/day, mean ± SD: 12.4 ± 4.3 | Urgency episodes/day, mean ± SD: 2.0 ± 3.0 P = NR Incontinence episodes/day, mean ± SD: 0.8 ± 2.0 P = NR Voids/day, mean ± SD: 7.7 ± 2.7 P = NR Urgency, successful treatment, OR (95% CI): Gender, M/F: 0.764 (0.583, 1.001) P = 0.0508 Age, years: 0.981 (0.973, 0.990) P < 0.001 Frequency, BL episodes/day: 1.038 (0.997–1.080) P = 0.0724 Urgency, BL episodes/day: 0.851 (0.823, 0.880) P < 0.001 Incontinence, BL episodes/day: 0.979 (0.950, 1.000) P = 0.1735 Tolterodine dose, mg/day: 0.913 (0.830, 1.005) P = 0.0623 Incontinence, successful treatment, OR (95% CI): Gender, M/F: 1.453 (1.062, 1.990) P = 0.0196 Age, years: 0.978 (0.968, 0.987) P < 0.001 Frequency, BL episodes/day: 1.034 (0.993, 1.076) P = 0.1036 Urgency, BL episodes/day: 1.053 (1.018, 1.088) P = 0.0027 Incontinence, BL baseline episodes/day: 0.744 (0.716, 0.774) P < 0.001 Tolterodine dose, mg/day: 0.866 (0.784, 0.956) P = 0.0043 Frequency, successful treatment, OR (95% CI): Gender, M/F: 0.745 (0.552, 1.004) P = 0.0532 Age, years: 0.981 (0.971, 0.991) P = 0.001 Frequency, BL episodes/day: 0.735 (0.701, 0.771) P < 0.001 Urgency, BL episodes/day: 1.008 (0.975, 1.041) P = 0.6526 Incontinence, BL episodes/day: 0.969 (0.937, 1.002) P = 0.0644 Tolterodine dose, mg/day: 1.070 (0.957, 1.196) P = 0.2335 Effect on Global efficacy, OR (95% CI): Gender, M/F: 0.656 (0.526, 0.818) P = 0.0002 Age, years: 0.986 (0.980, 0.993) P < 0.001 Frequency, BL epsidoes/day: 1.002 (0.972, 1.033) P = 0.8896 Urgency, BL episodes/day: 1.009 (0.984, 1.033) P = 0.4906 Incontinence, BL episodes/day: 0.963 (0.939, 0.987) P < 0.0026 Tolterodine dose, mg/day: 1.000 (0.926, 1.080) P = 0.9971 Effect on global tolerability of Tolterodine, OR (95% CI): Gender, M/F: 0.993 (0.790, 1.249) P = 0.9519 Age, years: 0.995 (0.988, 1.002) P = 0.1915 Frequency, BL episodes/day: 1.002 (0.971, 1.034) P = 0.8995 Urgency, BL episodes/day: 1.022 (0.997, 1.048) P = 0.0889 Incontinence, BL episodes/day: 0.990 (0.965, 1.016) P < 0.459 Tolterodine dose, mg/day: 1.114 (1.028, 1.206) P = 0.0085 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: − Loss to followup: + Drop-out rates: − Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Michel et al., 2007* Michel et al., 2005 Country and setting: Germany, NR Enrollment period: November 2001 to June 2003 Funding: Pharmacia (became Pfizer before publication) Author industry relationship disclosures: 5/5* 4SC (1) Astellas (1) Boehringer Ingelheim (2) Eli Lilly (2) Pfizer (4) Theravance (1) Anformed (1) | Design: Retrospective cohort, open label Intervention: Tolterodine ER Groups: G1: Incontinent G2: Continent N at enrollment: Total: 3,824 G1: 2,571 G2: 1,253 N at follow-up: Total: 3,416 Women, %: Total: 75.8 G1: 81.7 G2: 62.6 P < 0.001 Age, mean ± SD: Total: 64.8 ± 13.3 G1: 66.3 ± 12.6 G2: 61.4 ± 14.1 P < 0.001 Race/ethnicity: NR Follow-up: 9 months | Inclusion criteria: NR Exclusion criteria: NR | Urgency episodes/day, mean ± SD: Total: 7.9 ± 5.2 G1: 8.0 ± 5.2 G2: 7.7 ± 5.2 P = 0.1937 Incontinence episodes/day, mean ± SD: G1: 4.8 ± 3.7 G2: NA Voids/day, mean ± SD: Total: 14.0 ± 4.6 G1: 14.1 ± 4.6 G2: 13.5 ± 4.4 P < 0.001 Daytime voids/day, mean ± SD: Total: 10.7 ± 3.7 G1: 10.8 ± 3.7 G2: 10.4 ± 3.4 P = 0.0128 Frequency ≥ 8 voids/day, %: G1: 95.7 G2: 95.2 Nocturia episodes/day, mean ± SD: Total: 3.4 ± 1.7 G1: 3.5 ± 1.8 G2: 3.2 ± 1.6 P < 0.001 Pad use/day, mean ± SD: G1: 3.4 ± 2.8 G2: 0.1 ± 0.6 P < 0.001 Duration of symptoms (mo), mean ± SD: G1: 50 ± 53 G2: 40 ± 46 P < 0.001 Previous treatment, %: G1: 50.8 G2: 44.8 P = 0.0007 | Incontinence episodes/day, mean change ± SD: G1: −3.8 ± 3.5 G2: NA Urgency episodes/day, mean ± SD: Total: 1.6 ± 2.8 No urgency, %: G1: 53.4 G2: 63.2 Voids/day, mean ± SD: Total: 7.5 ± 3.0 Daytime voids/day, mean ± SD: Total: 6.2 ± 2.3 Frequency ≥ 8 voids/day, %: G1: 43.7 G2: 39.1 Nocturia episodes/day, mean ± SD: Total: 1.4 ± 1.1 Pad use/day, mean change ± SD: G1: −2.4 ± 2.5 Limitation of daily activities, score change ± SD: G1: 4.49 ± 2.65 G2: 4.10 ± 2.51 Limitations in daily life caused by bladder problems, score ± SD: G1: 7.59 ± 1.65 G2: 6.66 ± 1.69 P < 0.001 Total adverse events, n (%): Total: 496 (13.0) Dry mouth, n (%): 299 (7.8) Withdrew: 11% Unable to tolerate medication: 2.8% Administrative reasons: 2.6% Lack of efficacy: 2.4% Patient request: 1.2% | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: − Loss to followup: NR Drop-out rates: NA Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: + Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Moore et al., 1990 Moore and Sutherst 1990 Country and setting: UK, academic health center Enrollment period: NR Funding: Tillots Laboratories Author industry relationship disclosures: NR | Design: RCT with crossover Intervention: oxybutynin hydrochloride vs placebo Groups: G1:oxybutynin hydrochloride 3 mg tid G2:placebo N at enrollment: 53 N at follow-up: G1: 27 G2: 22 Age, mean ± SD: G1: 46.0 ± 11.7 G2: 46.4 ± 12.4 Race/ethnicity: NR Parity, mean: G1: 2.3 G2: 2.2 | Inclusion criteria: • UDS-defined idiopathic detrusor instability • Involuntary detrusor contractions > 30 cm H2O during filling phase of cystometry Exclusion criteria: • Neurological disorder • Urologic disorder • Age > 75 years • Genuine SI • Low-compliance bladder • Bacterial or interstitial cystitis • Previous treatment with oxybutynin | Voids/day, mean ± SD: G1: 11.1 ± 7.9 G2: 12.1 ± 5.7 Volume at first desire to void mean mL ± SD: G1: 94.2 ± 66 G2: 107.4 ± 101 Max detrusor filling pressure mean cm H2O, ±SD: G1: 55.3 ± 23 G2: 59.2 ± 26 Max cystometric capacity (mL) G1: 275 ± 164 G2: 290 ± 168 Residual urine volume mean mL ± SD: G1: 23.1 ± 34.2 G2: 22.7 ± 34.0 Duration of OAB, mean yrs ± SD): G1: 7.5 ± 7.9 G2: 8.9 ± 9.0 | Change in volume at first desire to void, period 1, mean mL ± SD (95% CI) G1: 70.0 ± 103 G2: 7.7 ± 76 G1/G2: P = 0.02 95% CI: (10, 113) Change in maximum detrusor filling pressure, mean ± SD: G1:−16.9 ± 19.5 G2:1.0 ± 28.7 G1/G2: P = 0.02 95% CI: (−32.5, −3.2) Change in maximum cystometric capacity, mean ± SD: G1:104.0 ± 131 G2:7.0 ± 103 G1/G2:p=0.006 95% CI: (29, 165) Change in residual urine Volume, period 1: G1: 22.4 (79.3) G2: 7.7 (45.7) P=0.42 Change in residual urine Volume, period 2: G1: 10.0 ± 27.1 G2: 25.7 ± 55.6 P = 0.33 Dry mouth on oxybutynin, %: 88 Dry mouth on placebo, %: 33 Mouth ulcers on oxybutynin, %: 16 Mouth ulcers on placebo, %: 0 Constipation on oxybutynin, % 12.5 Constipation on placebo, % 0 Drowsiness on oxybutynin, %: 12.5 Drowsiness on placebo, %: 7 Nausea on oxybutynin, %: 8.3 Nausea on placebo, %: 2.3 Initial hesitancy on oxybutynin, %: 4.2 Initial hesitancy on placebo, %: 2.3 Dizziness on oxybutynin, %: 4.2 Dizziness on placebo, %: 7.0 Metallic taste on oxybutynin, %: 2.4 Metallic taste on placebo, %: 2.3 Crown Crisp Experimental Index, >50% improvement:* Free floating anxiety: 6.4 Phobic anxiety: 5.3 Obsessionalism: 6.2 Somatic complaints: 6.2 Depression: 4.0 Hysteria: 2.6 Total: 30.7 Crown Crisp Experimental Index, <49% improvement:* Free floating anxiety: 8.8 Phobic anxiety: 6.8 Obsessionalism: 8.1 Somatic complaints: 8.9 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: − Statistical issues: − EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: ++ Measurement methods: + Measurement reliability: + Intervention description: +
Author: Rudy, et al. 2006 Rudy, et al. 2006 Staskin and Harnett, 2004 Country and setting: US; 52 sites Enrollment period: NR Funding: Indevus Author industry relationship disclosures: 5 of 5 Indevus (5) | Design: RCT Intervention: Trospium chloride vs placebo x 12 wks Groups: G1: trospium chloride 20 mg BID G2: matching placebo N at enrollment: G1: 329 G2: 329 N at follow-up: G1: 323 G2: 325 Age, mean yrs ± SE: G1: 61.1 ± 0.69 G2: 61.0 ± 0.70 Women, N (%): G1: 269 (81.8) G2: 267 (81.2) Race/ethnicity, n (%): Black: G1: 26 (7.9) G2: 21 (6.4) White: G1: 284 (86.3) G2: 300 (91.2) Hispanic: G1: 13 (4.0) G2: 5 (1.5) Asian: G1: 5 (1.5) G2: 3 (0.9) Parity: NR | Inclusion criteria: • 18+ years old • 6+ mos of OAB sx • 10+ voids/d • Sx of urgency • 7+ urge UIE/wk Exclusion criteria: • Predominantly SUI, insensate UI, or overflow UI • Neurogenic bladder d/o’s • Significant renal dz • Uninvestigated hematuria • UTI at washout or more than 2x during the prior 12 mos • PVR>100mL • Use of any anticholinergic drug or other drug therapy for OAB w/in 21 days before randomization • Bladder surgery w/in 6 mos before randomization • Cancer • Interstitial cystitis • PSA>10ng/mL • Diuretic use • Estrogen therapy • Nonmedical bladder therapy not part of a stable, long-term program • Pregnancy • Contraindication to antimuscarinic therapy | Daily voids, mean n: G1: 12.94 G2: 13.17 P=0.3169 Urgency severity score associated with toilet voids, median: G1: 1.79 G2: 1.75 P=0.4100 Volume voided in mL per void/24h, mean: G1: 154.80 ± NR G2: 154.64 ± NR P=0.9667 Median daily urge incontinence episodes: G1: 2.86 G2: 2.86 P=0.9849 Nocturnal voids/24 hr, median: G1: 2.00 G2: 2.00 P=0.9048 Nocturnal urgency severity score associated with toilet voids, mean: G1: 2.03 G2: 2.01 P=0.6863 OAB-SCS, median: G1: 36.56 G2: 36.88 P=0.7176 Stanford Sleepiness Scale, mean G1: 1.98 G2: 1.94 Stanford Sleepiness Scale, age group <65 years: G1: 1.99 G2: 2.09 Stanford Sleepiness Scale, age group >65 years: G1: 1.96 G2: 1.71 Stanford Sleepiness Scale, age group <75 years: G1: 2 G2: 1.97 Stanford Sleepiness Scale, age group >75 years: G1: 1.86 G2: 1.79 Prior OAB medications, n (%): G1: 162 (49.2) G2: 169 (51.4) Prior hx of pelvic-floor training, n (%): G1: 62 (18.8) G2: 76 (23.1) Currently practice undergarment change d/t incontinence, n (%): G1: 227 (69.0) G2: 239 (72.6) | Change from baseline to day 1: Daily voids, mean: G1: −0.66 G2: −0.35 P=0.14 Urgency severity score associated with toilet voids, mean: G1: 0.00 G2: 0.02 P=0.47 Median daily urge incontinence episodes: G1: −1.00 G2: −0.57 P=0.042 OAB-SCS, median: G1: −2.50 G2: −0.14 P=0.014 Change from baseline to [underlined: day 2] : Daily voids, mean: G1: −1.11 G2: −0.75 P=0.09 Urgency severity score associated with toilet voids, mean: G1: −0.08 G2: −0.03 P=0.13 Median daily UI episodes: G1: −1.29 G2: −0.86 P=0.0022 OAB-SCS, median: G1: −3.86 G2: −2.14 P=0.015 Change from baseline to [underlined: day 3] : Daily voids, mean: G1: −1.30 G2: −0.77 P=0.012 Urgency severity score associated with toilet voids, mean: G1: −0.11 G2: −0.04 P=0.015 Median daily UI episodes: G1: −1.57 G2: −0.86 P<0.0001 OAB-SCS, median: G1: −4.71 G2: −2.71 P=0.0019 Change from baseline to [underlined: day 4] : Daily voids, mean: G1: −1.33 G2: −0.95 P=0.086 Urgency severity score associated with toilet voids, mean: G1: −0.12 G2: −0.05 P=0.031 Median daily UI episodes: G1: −1.57 G2: −1.00 P<0.0001 OAB-SCS, median: G1: −4.86 G2: −3.36 P=0.011 Change from baseline to [underlined: day 5] : Daily voids, mean: G1: −1.73 G2: −1.12 P=0.0037 Urgency severity score associated with toilet voids, mean: G1: −0.13 G2: −0.05 P=0.021 Median daily UI episodes: G1: −1.57 G2: −1.00 P<0.0001 OAB-SCS, median: G1: −6.43 G2: −3.36 P<0.0001 Change from baseline to [underlined: day 6] : Daily voids, mean: G1: −1.80 G2: −1.28 P=0.017 Urgency severity score associated with toilet voids, mean: G1: −0.08 G2: 0.04 P<0.0001 Median daily UI episodes: G1: −1.71 G2: −1.00 P<0.0001 OAB-SCS, median: G1: −5.43 G2: −2.93 P<0.0001 Change from baseline to [underlined: week 1] : Daily voids, mean: G1: −1.42 G2: −0.96 P=0.0039 Urgency severity score associated with toilet voids, mean: G1: −0.09 G2: −0.01 P=0.0023 Volume voided in mL per void/24h: G1: 29.23 G2: 6.05 P<0.0001 Median daily urge incontinence episodes: G1: −1.43 G2: −0.86 P<0.0001 Nocturnal voids/24 hr, median: G1: −0.29 G2: −0.29 P=0.8454 Nocturnal urgency severity score associated with toilet voids, mean: G1: −0.05 G2: 0.03 P=0.0442 OAB-SCS, median: G1: −4.71 G2: −2.29 P<0.0001 Change from baseline to [underlined: 4 weeks:] Daily voids, mean: G1: −2.34 G2: −1.55 P<0.0001 Urgency severity score associated with toilet voids, mean: G1: −0.19 G2: −0.04 P<0.0001 Volume voided in mL per void/24h: G1: 39.50 G2: 9.45 P<0.0001 Median daily urge incontinence episodes: G1: −1.71 G2: −1.14 P<0.0001 Nocturnal voids/24 hr, median: G1: −0.43 G2: −0.29 P=0.0299 Nocturnal urgency severity score associated with toilet voids, mean: G1: −0.13 G2: =0.01 P=0.0062 OAB-SCS, median: G1: −8.14 G2: −3.86 P<0.0001 Change from baseline to [underlined: 12 weeks:] Daily voids. mean: G1: −2.67 G2: −1.76 P<0.0001 Urgency severity score associated with toilet voids: G1: −0.21 G2: −0.02 P<0.0001 Volume voided in mL per void/24h: G1: 35.59 G2: 9.44 P<0.0001 Daily UI episodes, median: G1: −1.86 G2: −1.29 P<0.0001 Nocturnal voids/d, median: G1: −0.57 G2: −0.29 P=0.0026 Nocturnal urgency severity score, mean: G1: −0.17 G2: 0.01 P=0.0005 OAB-SCS, median: G1: −8.43 G2: −4.62 P<0.0001 Adverse events Any, n (%) G1: 196 (59.6) G2:153 (46.5) Dry mouth: G1: 65 (19.8) G2: 17 (5.2) Constipation: G1: 36 (10.9) G2: 19 (5.8) Headache: G1: 18 (5.5) G2: 15 (4.6) UTI not otherwise specified: G1: 16 (4.9) G2: 8 (2.4) Nasopharyngitis: G1: 13 (4.0) G2: 12 (3.6) Cough: G1: 8 (2.4) G2: 1 (0.3) Diarrhea: G1: 7 (2.1) G2: 13 (4.0) AEs leading to treatment discontinuation, %: G1: 7.3 G2: 4.6 Most common AEs leading to discontinuation: Constipation: G1: 1.8% G2: 0.6% Dry mouth: G1: 1.5% G2: 0.0% Stanford Sleepiness Scale, change, wk 1: G1: −0.2 G2: −0.12 Stanford Sleepiness Scale, change wk 4: G1: −0.17 G2: −0.14 Stanford Sleepiness Scale, change, wk 12: G1: −0.16 G2: −0.11 Stanford Sleepiness Scale including T-max time point values only (G1=93, G2=97), change BL to week 1: G1: −0.42 G2: −0.2 Stanford Sleepiness Scale including T-max time point values only (G1=144, G2=148), change BL to week 4: G1: −0.2 G2: −0.19 Stanford Sleepiness Scale including T-max time point values only (G1=182, G2=179), change BL to week 12: G1: −0.17 G2: −0.18 Mean Stanford Sleepiness Scale, age group <65 years, change BL to week 1: G1: −0.27 G2: −0.19 Mean Stanford Sleepiness Scale, age group >65 years, change BL to week 1: G1: −0.04 G2: −0.03 Mean Stanford Sleepiness Scale, age group <65 years, change BL to week 4: G1: −0.14 G2: −0.27 Mean Stanford Sleepiness Scale, age group >65 years, change from baseline to week 4: G1: −0.23 G2: 0.03 Mean Stanford Sleepiness Scale, age group <65 years, change from baseline to week 12: G1: −0.14 G2: −0.22 Mean Stanford Sleepiness Scale, age group >65 years, change from baseline to week 12: G1: −0.22 G2: 0.03 Mean Stanford Sleepiness Scale, age group < 75 years, change from baseline to week 1: G1: −0.21 G2: −0.14 Mean Stanford Sleepiness Scale, age group > 75 years, change from baseline to week 1: G1: −0.02 G2: 0 Mean Stanford Sleepiness Scale, age group < 75 years, change from baseline to week 4: G1: 0.14 G2: −0.16 Mean Stanford Sleepiness Scale, age group > 75 years, change from baseline to week 4: G1: −0.49 G2: −0.09 Mean Stanford Sleepiness Scale, age group < 75 years, change from baseline to week 12: G1: 0.15 G2: −0.14 Mean Stanford Sleepiness Scale, age group > 75 years, change from baseline to week 12: G1: −0.33 G2: 0.02 At least one CNS event: G1: 5.8% G2: 5.2% Somnolence G1: 0.3% G2: 0.6% Sedation: G1: 0 G2: 0.3% Clinically significant increase (≤ 3 points) from baseline to week 12 in SSS score, n (%): G1: 5 (1.5) G2: 8 (2.5) | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: − Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: + Length of followup: + Measurement methods: + Measurement reliability: − Intervention description: +
Author: Salvatore et al., 2007 Country and setting: Italy, Urogynecology outpatient clinic Enrollment period: January 2004 to October 2005 Funding: NR Author industry relationship disclosures: NR | Design: Cohort Intervention: Tolterodine SR 4 mg qd Groups: G1: vaginal profile stage 0a or Ia G2: anterior prolapse ≥ stage IIa N at enrollment: G1: 184 G2: 51 N at follow-up: NR Women, %: 100 Age, median (range): G1: 59 (20, 85) G2: 59 (35, 82) Race/ethnicity: NR Parity, mean (range): G1: 2 (0–6) G2: 2 (0–6) Menopausal, n (%): G1: 132 (72) G2: 7 (18) | Inclusion criteria: Women Urodynamically proven OAB who had no prolapse or pure anterior vaginal prolapse Proven detrusor overactivity Exclusion criteria: All symptoms or signs related to voiding difficulties Prolapse | Previous surgery, n (%): G1: 52 (28) G2: 11 (22) HRT, n (%) G1: 35 (26) G2: 7 (18) | Improvement in condition or cured, n (%): G1: 158 (85.9) G2: 31 (60.8)* P = 0.0002 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Masking: NA Pt selection criteria: + Loss to followup: NR Drop-out rates: NR Power calculation: − Statistical issues: − EXTERNAL VALIDITY: poor Age: + Baseline OAB status: NR Baseline characteristics: − Length of followup: + Measurement methods: − Measurement reliability: − Intervention description: +
Author: Sand et al., 2004 Country and setting: US, Specialty clinic Enrollment period: Subanalysis of OBJECT trial, women only Funding: ALZA Corp Author industry relationship disclosures: NR | Design: RCT Intervention: 10mg ER Oxybutynin daily vs 4mg Tolterodine (2mg bid) Groups: G1: 10mg ER Oxybutynin daily x 12 wks G2: 4mg Tolterodine (2mg bid) x 12 wks Stratified by age: a: Age ≤ 64 b: Age 65–74 c: Age ≥ 75 N at enrollment: G1: 152 G2: 163 N at follow-up: G1: 132 G2: 146 Women, %: 100 Age, yrs ± SD: G1: 58.4 G2: 58.8 Race/ethnicity: NR | Inclusion criteria: • ≥ 7 and ≤ 50 UUI episodes/week • ≥ 10 voids/day • MUI included if predominant UUI Exclusion criteria: • UTI • IC • Urethral diverticulum • Bladder tumor • Bladder stone • Delivery within 6 mos • Pelvic, bladder, vaginal surgery in ≤ 6 mos • PVR ≥ 150 mL • CV, renal, pulmonary, GI, endocrine, neurologic, autoimmune, hematological, urological, psychiatric, or hepatic disease • Hematuria • Positive urine culture • Narrow angle glaucoma • Obstructive uropathy • Myasthenia gravis • POP to hymenal ring • Gastrointestinal obstruction • Decreased GI motility • GI narrowing • GI retention • Investigational drugs within 1 month of screening • Hypersensitivity to drugs • Current drug/EtOH abuse • Pregnant • Breastfeeding • Inability to follow protocol | UUI episodes/week, mean: G1: 25.2 G2: 25.1 Incontinence episodes/week, mean: G1: 28.1 G2: 28.9 Voids/week, mean: G1: 91.7 G2: 91.6 Naïve to anti-cholinergics, %: G1: 60.5 G2: 60.7 | UUI episodes/week, %: G1: 6.2 G2: 8.5 G1a: 5.0 G2a: 8.4 G1b: 5.5 G2b: 7.5 G1c: 8.5 G2c: 11.1 G1/G2: P = 0.038 G1a/G2a: P = 0.005 G1b/G2b: P = 0.337 G1c/G2c: P = 0.568 Incontinence episodes/week, mean: G1: 7.3 G2: 10.1 G1a: 5.8 G2a: 10.0 G1b: 6.1 G2b: 9.2 G1c: 10.5 G2c: 12.5 G1/G2: P = 0.030 G1a/G2a: P = 0.005 G1b/G2b: P = 0.164 G1c/G2c: P = 0.714 Voids/week, mean: G1: 68.0 G2: 71.2 G1a: 63.7 G2a: 71.2 G1b: 73.8 G2b: 71.9 G1c: 66.8 G2c: 65.5 G1/G2: P = 0.272 G1a/G2a: P = 0.024 G1b/G2b: P = 0.706 G1c/G2c: P = 0.838 Dry mouth, %: G1: 28.3 G2: 33.7 Constipation, %: G1: 8.6 G2: 6.7 Retention, %: G1: 4.0 G2: 1.2 Blurred vision, %: G1: 2.6 G2: 0.6 Dizziness, %: G1: 3.9 G2: 4.3 Insomnia, %: G1: 0.7 G2: 1.8 Somnolence, %: G1: 3.3 G2: 1.8 Nervousness, %: G1: 0 G2: 1.2 Headache, %: G1: 9.2 G2: 10.4 Dyspepsia, %: G1: 5.3 G2: 6.1 Nausea, %: G1: 3.3 G2: 1.8 Vomiting, %: G1: 2.0 G2: 1.8 | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: + Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Serati et al, 2008 Country and setting: NR; Urogynecology unit Enrollment period: January 2005 to December 2006 Funding: NR Author industry relationship disclosures: None | Design: Prospective case series Intervention: Tolterodine ER 5 mg qd (prescribed to women with proven pure DO w/o SUI) Groups: G1: Coital incontinence at orgasm G2: Coital incontinence during penetration G3: DO + coital incontinence at orgasm (sub-group of G1) G4: DO w/o coital incontinence (controls) N at enrollment: G1: 49 G2: 83 G3: 34 G4: 53 N at follow-up: NR Age, median (range): G1–G2: 51 (22–70) G3: 50 (22–66) G4: 51 (19–68) BMI (kg/m ^2^ ), median (range): G1–G2: 24.1 (17–43) G3: 25.3 (17–43) G4: 26 (19–35) Race/ethnicity: NR Postmenopausal, n (%): G1–G2: 59 (44.7) G3: 14 (41.2) G4: 19 (35.8) Parity, median (range): G1-G2: 2 (0–5) G3: 2 (0–5) G4: 2 (0–4) Nulliparous, n (%): G1-G2: 7 (5.3) G3: NR G4: NR Follow-up: 12 weeks | Inclusion criteria: • Sexually active women with UI Exclusion criteria: • Documented UTI • Previous anti-muscarinic trt • POP-Q ≥ Stage 2 • Refusal to answer questions about sex life | Type of UI, n (%): DO: G1: 34 (69.4) G2: 13 (15.7) P < 0.0001 SUI: G1: 5 (10.2) G2: 40 (48.2) MUI: G1: 0 G2: 11 (13.2) Inconclusive: G1: 10 (20.4) G2: 19 (22.9) | Non-responders to trt, n (%): G3: 14 (41.2) G4: 9 (17) P = 0.023 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: NA Method and blinding: NA Pt selection criteria: + Loss to followup: ++ Drop-out rates: ++ Power calculation: − Statistical issues: − EXTERNAL VALIDITY: fair Age: + Baseline OAB status: NR Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: − Intervention description: +
Author: Steers et al., 2007 Country and setting: Australia, Canada, US; multicenter, 30 centers Enrollment period: July 2001 to September 2003 Funding: Eli Lilly FVC - frequency volume chart DOA - detrusor overactivity SU - sensory urge PVR - postvoid residual urine BL - baseline PGI-I-Patient Global Impression of Improvement TEAEs= Treatment emergent adverse events | Design: RCT, placebo-controlled, double-blind, stratified by urodynamic observation (DOA Intervention: duloxetine vs placebo Groups: G1: placebo × 2 wks, duloxetine 40 mg bid × 4 wks, duloxetine 60 mg bid × bid 8 wks G2: placebo bid × 14 wks N at enrollment: G1: 153 G2: 153 N at follow-up, N (%): G1: 90 (59) G2: 120 (78) Age, mean ± SD: G1: 56.0 ± 14.8 G2: 53.3 ± 14.1 Women, N (%): 306 (100) BMI, mean kg/m2 ± SD: G1: 29.2 (7.4) G2: 30.2 (7.8) | Inclusion criteria: • women • >18 yoa • predominant symptoms of OAB ≥ 3 months defined as bothersome urinary urgency and/or urge, abnormal voiding frequency (≤ 2 h mean daytime voiding interval) • UDS observation of either detrusor OA or urgency that limited bladder capacity to <400mL Exclusion criteria: • -SUI • PVR >100 mL • Mean 24 h total volume voided of ≥ 3L • Urine culture • ≥4 UTIs in past yr • Regular use of meds for OAB w/in 4wks of enrollment • Previous use of duloxetine • Continence surgery ≤ 6 mos • Any major surgery ≤ 3 mos • Pelvic organ prolapse > ICS Stage II • Non-pharm intervention ≤ 3 mos • PFM training that had not been stable for 3 mos or would not remain stable during the trial | Void per 24 hrs: G1: 10.76 G2:: 10.49 Daytime VI G1: 113.58 G2: 119.63 Urinary incontinence episodes(all assessable pts): G1: 1.70 G2: 1.44 Urinary incontinence episode (wet OAB): G1: 2.34 G2: 2.07 Continence pads/wk: G1: 7.81 G2: 7.05 Volume voided, mL: G1: 175.41 G2: 183.40 Nocturia episodes/d: G1: 1.47 G2: 1.63 Quality of Life Instrument score, mean ± SD: I-QOL G1: 56.65 ± 24.80 G2: 57.11 ± 23.3 U-IIQ: G1: 2.44 ± 1.18 G2: 2.39 ± 1.15 U-UDI: G1: 3.18 ± 0.58 G2: 3.15 ± 0.71 Bladder compliance (mL/cmH20) G1: 71.8 ± 85.7 G2: 79.3 ± 91.0 SUI: G1: 0 G2: 0 Maximum cystometric capacity mL G1: 318.3 ± 152.4 G2: 330.4 ± 135.4 Volume threshold for first detrusor contraction mL G1: 226.4 ± 141.8 G2: 250.6 ± 146.0 Moderate or severe bladder condition from PGI-I Scale (%): G1: 84.9 G2: 88.8 I-QOL total score, mean ± SD: G1: 56.6 (24.9) G2: 57.0 (23.2) UIE, mean ± SD: G1: 1.55 (2.08) G2: 1.41 (2.00) VE24, mean ± SD: G1: 10.8 (3.3) G2: 10.6 (3.6) Symptom of bothersome urgency, %: G1: 99.3 G2: 99.3 Symptoms of urge UI, %: G1: 88.2 G2: 88.9 Symptoms of SUI: G1: 42.5 G2: 50.3 Urodynamic DOA G1: 42.5 G2: 41.8 Sensory urgency: G1: 57.5 G2: 58.2 Previous continence surgery, %: G1: 13.1 G2: 11.8 Current pelvic-floor muscle training, %: G1: 9.2 G2: 11.8 Previous behavioral therapy, %: G1: 3.3 G2: 2.6 Previous tolterodine therapy, %: G1: 10.5 G2: 7.2 Previous oxybutynin therapy, %: G1: 13.0 G2: 9.2 | VE24 G1: −1.81 G2:: −0.62 G1vG2, P<0.001 Daytime VI G1: 29.46 G2: 6.51 G1vG2, P<0.001 UIE (all assessable pts) G1: −0.74 G2: −0.14 p=0.006 UIE (wet OAB) G1: −1.03 G2: −0.24 p=0.032 Continence pads/wk: G1: −1.41 G2: −0.53 P=0.143 Volume voided, mL: G1: 8.85 G2: 5.07 P=0.171 Nocturia episodes/d: G1: 0.05 G2: −0.18 p=0.004 8/12 wks (120 mg/day) G1: 61.6 G2: 42.1 p=0.008 Overall: G1: 53.4 G2: 41.9 G=0.052 Headache: G1: 13 (8.5) G2: 8 (5.2) p=0.336 Diarrhea: G1: 10 (6.5) G2: 5 (3.3) p=0.289 Cough: G1: 7 (4.6) G2: 6 (3.9) p>0.999 Change in QoL Instrument score, mean ± SD: I-QOL G1: 8.37 ± 15.89 G2: 4.87 ± 15.27 G1>G2 (P=.035) U-IIQ G1: −0.44 ± 0.76 G2: −0.22 ± 0.87 P=0.018 U-UDI G1: −0.26± 0.67 G2: −0.19 ± 0.59 P=0.440 Bladder compliance (mL/cmH20) G1: 16.5 ±131.3 G2: 1.0 ± 120.8 P=0.655 Maximum cystometric capacity mL G1: 22.1 ± 116.4 G2: 23.8 ± 108.5 P=0.619 Volume threshold for first detrusor contraction mL G1: 90.0 ± 200.6 G2: 13.9 ± 112.8 P=0.254 PGI-I score Better 4 wks (80 mg/day) G1: 59.9 G2: 42.9 p=0.005 TEAEs reported, % G1: 79.1 G2: 55.6 P<0.001 Appetite decreased G1: 6 (3.9) G2: 0 G1>G2, p=0.030 Arthralgia G1: 6 (3.9) G2: 3 (2.0) p=0.501 Somnolence: G1: 6 (3.9) G2: 0 p=0.30 Sweating increased: G1: 6 (3.9) G2: 2 (1.3) p=0.283 UTI: G1: 6 (3.9) G2: 6 (3.9) p>0.999 Anorgasmia G1: 5 (3.3) G2: 0 G1>G2, p=0.060 Anxiety: G1: 5 (3.3) G2: 0 G1>G2, p=0.060 Tremor: G1: 5 (3.3) G2: 0 G1>G2, p=0.060 Upper respiratory infection: G1: 5 (3.3) G2: 4 (2.6) p>0.999 Vomiting: G1: 5 (3.3) G2: 3 (2.0) p=0.723 Abdominal pain: G1: 4 (2.6) G2: 1 (0.7) p=0.371 Back pain: G1: 4 (2.6) G2: 1 (0.7) p=0.371 Note: mean change consistent at 4 wks (duloxetine 80 mg/d) and 8 wks (duloxetine 120 mg/d) Change in I-QOL total score, mean ± SD: Discontinuation due to TEAEs, % G1: 28.1 G2: 5.2 p<0.001 Treatment emergent adverse events, n (%): Nausea: G1: 47 (30.7) G2: 7 (4.6) G1>G2, p<0.001 Dry mouth: G1: 25 (16.3) G2: 2 (1.3) G1>G2, p<0.001 Dizziness: G1: 22 (14.4) G2: 1 (0.07) G1>G2, p<0.001 Constipation: G1: 21 (13.7) G2: 5 (3.3) G1>G2, p=0.002 Insomnia: G1: 20 (13.1) G2: 5 (3.3) G1>G2, p=0.003 Fatigue: G1: 16 (10.5) G2: 3 (2.0) G1>G2, p=0.003 | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: − Drop-out rates: ++ Power calculation: + Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Sussman and Garely, 2002 Country and setting: US; 2 sites Enrollment period: NR Funding: NR Author industry relationship disclosures: NR | Design: Multicenter RCT Intervention: Tolterodine ER vs. Oxybutynin ER Groups: G1: Tolterodine ER 2 mg qd x 8 wks G2: Tolterodine ER 4 mg qd x 8 wks G3: Oxybutynin ER 5 mg qd x 8 wks G4: Oxybutynin ER 10 mg qd x 8 wks N at enrollment: G1: 333 G2: 336 G3: 313 G4: 307 N at follow-up: G1: 313 (86) G2: 316 (88) G3: 286 (81) G4: 285 (79) Age, yrs ± SD: G1: 63.8 ± 15.7 G2: 63.4 ± 16.6 G3: 59.8 ± 16.5 G4: 63.2 ± 15.9 Women, N (%): G1: 243 (73) G2: 254 (76) G3: 245 (78) G4: 222 (72) Race/ethnicity, n (%): White: G1: 278 (84) G2: 296 (88) G3: 256 (82) G4: 247 (81) Black: G1: 28 (8) G2: 23 (7) G3: 41 (13) G4: 42 (14) Hispanic: G1: 19 (6) G2: 15 (5) G3: 15 (5) G4: 16 (5) Other, n (%): G1: 8 (2) G2: 2 (<1) G3: 1 (<1) G4: 2 (<1) Parity: NR | Inclusion criteria: •18+ years old •OAB (urinary frequency + urgency) w/or w/o UI Exclusion criteria: •Pure SUI •Urinary retention •Gastric retention •Uncontrolled narrow-angle glaucoma •Hepatic or renal dysfunction •Symptomatic or recurrent UTI •ES •BT •Pelvic floor exercise w/in 1 wk of first study visit or expected to start during study •Indwelling catheter •Intermittent self-catherization •Contraindication to antimuscarinic trt •Estrogen therapy started less than 2 mos prior to first visit •Any treatment for UI w/in 1 wk of first visit •Use of anticholinergic drug or potent inhibitors of cytochrome P450 3A4 •Pregnant •Lactating •Childbearing potential w/o adequate contraception | Presence of UI, n (%): G1: 195 (59) G2: 214 (64) G3: 199 (64) G4: 195 (64) [underlined: Duration of sx, n (%):] <6 mos G1: 38 (11) G2: 48 (14) G3: 62 (20) G4: 43 (14) 6mos-5yrs: G1: 226 (68) G2: 224 (67) G3: 183 (59) G4: 205 (67) >5yrs: G1: 68 (20) G2: 64 (19) G3: 67 (21) G4: 59 (19) Severity of bladder condition, % No problems: G1: 1.3 G2: 0.3 G3: 1.0 G4: 0.7 Some very minor problems: G1: 6 G2: 5 G3: 5 G4: 5 Some minor problems: G1: 18 G2: 16 G3: 21 G4: 15 Moderate problems G1: 45 G2: 50 G3: 41 G4: 47 Severe problems: G1: 26 G2: 21 G3: 23 G4: 25 Many severe problems: G1: 4 G2: 7 G3: 8 G4: 8 | Bladder Condition Questionnaire Improvement in bladder condition at 8 wks, %: Overall G1: 60 G2: 70 G3: 59 G4: 60 G2 vs G3 p<0.01 G2 vs G4 p<0.01 Pts with moderate or severe bladder condition: G2: 77 G4: 65 G2 vs G4 p<0.01 Treatment naive G1: 60 G2: 69 G3: 60 G4: 61 p=0.11 for improvement rates p>0.05 for overall difference btw trt arms Treatment experienced G1: 57 G2: 75 G3: 59 G4: 54 p=0.11 for improvement rates p>0.05 for overall difference btw trt arms Adverse Events Withdrawal d/t AE, (%): G2: 6 G4: 13 P=0.001 Mean change in severity of dry mouth (visual analogue scale): G1: 2.3 G2: 6.0 G3: 6.3 G4: 11.3 G1 vs G2: p=NS G3 vs G4: p=0.05 G2 vs G4: p=0.03 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: + Masking: − Pt selection criteria: + Loss to followup: − Drop-out rates: − Power calculation: − Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Swift et al., 2003 Country and setting: Europe (167 centers), North America (74 centers), Australia and New Zealand (4 centers), University Enrollment period: February 1999 to October 1999 Funding: Pharmacia Corp Author industry relationship disclosures: NR | Design: RCT double blind placebo-controlled double dummy, random permuted blocks of 6 Intervention: Tolterodine ER vs. Tolterodine IR Groups: G1: Tolterodine ER 4mg daily G2: Tolterodine IR 2 mg BID G3: placebo N at enrollment: G1: 417 G2: 408 G3: 410 N at follow-up: Total: 1092 Women, %: 100 Age, yrs ± SD: G1: 59 ± 14 G2: 59 ± 14 G3: 60 ± 14 Race/ethnicity, n (%): White: G1: 396 (95) G2: 389 (95) G3: 383 (93) Black: G1: 15 (4) G2: 12 (3) G3: 20 (5) Asian/Pacific: G1: 5 (1) G2: 4 (1) G3: 2 (1) Mixed: G1: 0 G2: 3 (1) G3: 5 (1) Unknown: G1: 1 (<1) G2: 0 G3: 0 BMI, kg/m^2^ ± SD: G1: 28.8 ± 13.8 G2: 29.0 ± 11.0 G3: 28.8 ± 6.7 | Inclusion criteria: • Women • Age ≥ 18 • ≥ 8 voids/day • > 5 UUI/week • Symptoms x ≥ 6 months (per voiding diary) Exclusion criteria: • SUI • Total daily urine volume > 3 liters • Hepatic/renal disease • UTI • IC • Hematuria • BOO • Current e-stim • Current bladder training • Indwelling catheter • CIC • Pregnant/nursing • Childbearing age without BC • Anticholinergic meds • Meds inhibit cytochromep450 | Incontinence episodes/week, mean ± SD: G1: 22.1 ± 22.5 G2: 22.9 ± 21.9 G3: 23.9 ± 21.2 Pads/day, mean ± SD: G1: 1.6 ± 2.1 G2: 1.5 ± 2.0 G3: 1.7 ± 2.4 Voids/day, mean ± SD: G1: 10.8 ± 4.2 G2: 11.1 ± 3.7 G3: 11.2 ± 3.9 Voided volume (mL), mean ± SD: G1: 141.2 ± 43.1 G2: 137.2 ± 41.2 G3: 135.7 ± 43.2 Previous drug therapy: n (%): G1: 235 (56) G2: 222 (54) G3: 225 (55) | Incontinence episodes/week, mean ± SD: G1: 10.3 ± 17.2 G2: 12.8 ± 19.8 G3: 16.7 ± 19.7 G1/G3: P = 0.001 G2/G3: P = 0.001 Pads/day, mean ± SD: G1: 1.0 ± 1.8 G2: 1.0 ± 1.5 G3: 1.5 ± 2.2 G1/G3: P = 0.001 G2/G3: P = 0.001 Voids/day, mean ± SD: G1: 9.0 ± 3.2 G2: 9.3 ± 4.0 G3: 9.9 ± 3.8 G1/G3: P = 0.001 G2/G3: P = 0.005 Voided volume (mL), mean ± SD: G1: 179.1 ± 66.6 G2: 169.7 ± 65.6 G3: 149.0 ± 56.3 G1/G3: P = 0.001 G2/G3: P = 0.001 Clinical effect-tiveness*, dry mouth: G1: 0.53 G2: 0.39 G3: 0.30 Dry mouth, n (%): G1: 105 (25.3) G2: 127 (31.2) G3: 33 (8.0) G1/G3: P < 0.01 G2/G3: P < 0.01 Abdominal pain, n (%): G1: 18 (4.3) G2: 12 (2.9) G3: 7 (1.7) G1/G3: P = 0.03 Constipation, n (%): G1: 27 (6.5) G2: 27 (6.6) G3: 14 (3.4) Dyspepsia, n (%): G1: 11 (2.7) G2: 14 (3.4) G3: 6 (1.5) Nausea, n (%): G1: 7 (1.7) G2: 9 (2.2) G3: 9 (2.2) Diarrhea, n (%): G1: 10 (2.4) G2: 14 (3.4) G3: 9 (2.2) Flatulence, n (%): G1: 8 (1.9) G2: 11 (2.7) G3: 6 (1.5) Xerophthalmia, n (%): G1: 16 (3.9) G2: 8 (2.0) G3: 8 (2.0) Abnormal vision, n (%): G1: 5 (1.2) G2: 4 (1.0) G3: 2 (0.5) Headache, n (%): G1: 29 (7.0) G2: 14 (3.4) G3: 19 (4.6) UTI, n (%): G1: 15 (3.6) G2: 11 (2.7) G3: 19 (4.6) Insomnia, n (%): G1: 7 (1.7) G2: 2 (0.5) G3: 9 (2.2) Somnolence, n (%): G1: 12 (2.9) G2: 11 (2.7) G3: 8 (2.0) Dizziness, n (%): G1: 7 (1.7) G2: 7 (1.7) G3: 4 (1.0) Hypertension, n (%): G1: 6 (1.4) G2: 4 (1.0) G3: 4 (1.0) Sinusitis, n (%): G1: 8 (1.9) G2: 2 (0.5) G3: 3 (0.7) Arthritis, n (%): G1: 1 (0.2) G2: 5 (1.2) G3: 1 (0.2) Dry skin, n (%): G1: 2 (0.5) G2: 5 (1.2) G3: 1 (0.2) | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: + Masking: + Pt selection criteria: + Loss to followup: ++ Drop-out rates: ++ Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Van Kerrebroeck et al., 2002 Freeman et al., 2003* Country and setting: North America (74 centers), Australasia (4 centers), Europe (89 centers) Enrollment period: NR Funding: Pharmacia Corporation Author industry relationship disclosures: NR | Design: RCT Intervention: Tolterodine ER vs Tolterodine IR vs placebo Groups: G1: tolterodine ER 4 mg sid G2: tolterodine IR 2 mg bid G3: placebo N at enrollment: G1: 507 G2: 514 G3: 508 N at follow-up: Total: 1442 G1: 398 G3: 374 Women, n (%): G1: 417 (82) G2: 408 (79) G3: 410 (81) Age, mean (range): G1: 60 (20, 89) G2: 60 (22, 92) G3: 61 (22, 93) Race/ethnicity, %:* White: G1: 95.7 G3: 94.7 Black: G1: 3.0 G3: 3.5 Asian/Pacific Islander: G1: 1.0 G3: 0.8 Other: G1: 0.3 G3: 1.1 | Inclusion criteria: • Age ≥ 18 • Urinary frequency (≥ 8 voids/day) Exclusion criteria: • SUI • Total daily urine volume > 3 L • Contra-indications to antimuscarinic treatment • Hepatic or renal disease • UITs • Interstitial cystitis • Hematuria • BOO • Current electrostimulation or bladder training therapy • Indwelling catheter or intermittent self-catheterization • Pregnant or nursing • Women not using reliable contraception • Being treated for OAB with other anticholinergic drugs or drugs that inhibit cytochrome P450 3A4 isoenzymes • Estrogen therapy < 2 months • Treatment w/investigational drug < 2 months | Incontinence episodes/week, mean (range): G1: 22.1 (0, 168.0) G2: 23.2 (0, 168.0) G3: 23.3 (0, 168.0) ≥ 5 incontinence episodes/week, n (%): G1: 492 (97) G2: 498 (97) G3: 494 (97) Pads/day, mean (range): G1: 1.4 (0–18) G2: 1.4 (0–25) G3: 1.5 (0–22) Voids/day, mean (range): G1: 10.9 (2.3, 51.3) G2: 11.1 (2.0, 48.6) G3: 11.3 (2.0, 37.4) ≥ 8 voids/day, n (%): G1: 458 (90) G2: 469 (91) G3: 467 (92) Previous drug therapy, n (%): G1: 270 (53) G2: 276 (54) G3: 263 (52) Poor efficacy, %: G1: 43 G2: 38.4 G3: 40.7 Able to finish tasks before visiting a toilet, %:* G1: 5 G3: 6 Voided volume (mL), mean (range): G1: 141 (36, 338) G2: 137 (38, 283) G3: 136 (31, 374) | Urinary Urgency, subjective assessment, 12 wks, n (%):* Improvement: G1: 173 (44) G3: 118 (32) G1/G3: P < 0.001 No change: G1: 201 (51) G3: 212 (57) Deterioration: G1: 22 (6) G3: 44 (12) G1/G3: P < 0.002 Urinary urgency, improvement, 12 wks, women only, %:* G1: 46.6 G3: 26.6 G1/G3: P = 0.001 OR 1.81 (95% CI: 1.31, 2.49) Not able to hold urine, 12 wks, %:* G1: 58 G3: 32 G1/G3: P < 0.001 Incontinence episodes/week, mean change ± SD (%) G1: −11.8 ± 17.8 G2: −10.6 ± 16.9 G3: −6.9 ± 15.4 G1/G3: P = 0.00001 G2/G3: P = 0.0005 G1/G2: P < 0.05 Incontinence episodes/week, median % change: G1: −71 G2: −60 G3: −30 G1/G2: P < 0.05 Pads/day, mean ± SD: G1: −0.5 ± 1.4 G2: −0.5 ± 18 G3: −0.2 ± 1.4 G1/G3: P = 0.0145 G2/G3: P = 0.0035 Voids/day, mean ± SD: G1: −3.5 ± 4.9 G2: −3.3 ± 4.4 G3: −2.2 ± 4.0 G1/G3: P = 0.00001 G2/G3: P = 0.0002 Voluntary voids/day, mean ± SD: G1: −1.8 ± 3.4 G2: −1.7 ± 3.3 G3: −1.2 ± 2.9 G1 vs G3 G1/G3: P = 0.00047 G2/G3: P = 0.0079 Bladder symptoms, improvement, 12 wks, women only, %:* G1: 62.8 G3: 48.4 G1/G3: P = 0.001 OR 1.78 (95% CI: 0.34, 2.37) Treatment benefit, 12 wks, n (%):* Much benefit: G1: 172 (43.2) G3: 88 (23.5) G1/G3: P < 0.001 Little benefit G1: 138 (34.7) G3: 118 (31.6) No benefit G1: 88 (22.1) G3: 168 (44.9) Able to finish tasks before visiting a toilet, 12 wks, %:* G1: 33 G3: 18 G1/G3: P < 0.001 Voided volume (mL), mean change ± SD: G1: +34 ± 51 G2: +29 ± 47 G3: +14 ± 41 G1/G3: P = 0.00001 G2/G3: P = 0.0001 Discontinued due to AEs, n (%): G1: 27 (5) G2: 28 (5) G3: 33 (6) Reported serious adverse events, n: G1: 7 G2: 12 G3: 18 Parasympathetic Dry mouth, n (%): G1: 118 (23) G2: 156 (30) G3: 39 (8) Xerophthalmia, n (%): G1: 17 (3) G2: 12 (2) G3: 10 (2) Abnormal vision, n (%): G1: 6 (1) G2: 4 (1) G3: 2 (0.5) Dry skin, n (%): G1: 2 (0.5) G2: 6 (1) G3: 1 (0.5) Gastrointestinal Constipation, n (%): G1: 30 (6) G2: 35 (7) G3: 22 (4) Dyspepsia, n (%): G1: 15 (3) G2: 16 (3) G3: 7 (1) Abdominal pain, n (%): G1: 19 (4) G2: 13 (3) G3: 8 (2) Diarrhea, n (%): G1: 10 (2) G2: 16 (3) G3: 11 (2) Flatulence, n (%): G1: 10 (2) G2: 14 (3) G3: 9 (2) Nausea, n (%): G1: 7 (1) G2: 10 (2) G3: 10 (2) Headache, n (%): G1: 32 (6) G2: 19 (4) G3: 23 (5) Somnolence, n (%): G1: 14 (3) G2: 13 (3) G3: 9 (2) Dizziness, n (%): G1: 11 (2) G2: 9 (2) G3: 5 (1) Fatigue, n (%): G1: 11 (2) G2: 6 (1) G3: 4 (1) Insomnia, n (%): G1: 7 (1) G2: 2 (0.5) G3: 9 (2) Urinary tract infection, n (%): G1: 16 (3) G2: 13 (3) G3: 20 (4) Dysuria, n (%): G1: 5 (1) G2: 8 (2) G3: 1 (0.5) Peripheral edema, n (%): G1: 7 (1) G2: 7 (1) G3: 4 (1) | Quality: Overall quality score: fair INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: − Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +
Author: Zinner et al., 2002 [See evidence table for Van Kerrebroeck et al., 2001} Country and setting: North America (74 centers), Australasia (4 centers), Europe (89 centers) Enrollment period: NR Funding: Pharmacia Corporation Author industry relationship disclosures: NR | Design: RCT Intervention: Tolterodine ER vs. placebo Groups: G1: tolterodine ER 4 mg qd < 65 years of age G2: placebo < 65 years of age G3: tolterodine ER 4 mg qd ≥ 65 years of age G4: placebo ≥ 65 years of age N at enrollment: G1: 293 G2: 285 G3: 214 G4: 223 N at follow-up: G1: 257 G2: 246 G3: 193 G4: 194 Women, n (%): G1: 255 (87)** G2: 247 (87)** G3: 162 (76) G4: 163 (73) Age, mean ± SD: G1: 51 ± 10.5 G2: 51 ± 10 G3: 74 ± 6 G2: 74 ± 6 Race/ethnicity: NR | Inclusion criteria: • Age ≥ 18 • Urinary frequency (≥ 8 voids/day) Exclusion criteria: • Demonstrable SUI • Total daily urine volume > 3 L • Contra-indications to antimuscarinic treatment • Hepatic or renal disease • UTI • Interstitial cystitis • Hematuria • BOO • Current electrostimulation or bladder training therapy • Indwelling catheter or intermittent self-catheterization • Pregnant or nursing • Women not using reliable contraception • Being treated for OAB with other anticholinergic drugs or drugs that inhibit cytochrome P450 3A4 isoenzymes • Estrogen therapy < 2 months Treatment w/investigational drug < 2 months | Not able to hold urine upon experiencing urgency, %: G1: 24.9 G2: 29.1 G3: 33.6 G4: 34.5 Able to complete tasks before toilet visit in response to urgency,%: G1: 6.5 G2: 7.7 G3: 5.1 G4: 4.9 Incontinence episodes/week, mean ± SD: G1: 21.4 ± 22.1 G2: 23.2 ± 22.0 G3: 23.2 ± 22.7 G4: 23.4 ± 18.9 Voids/day, mean ± SD: G1: 11.0 ± 3.9 G2: 11.4 ± 4.2 G3: 10.8 ± 4.5 G4: 11.0 ± 3.2 Voided volume (mL), mean ± SD: G1: 140 ± 41 G2: 137 ± 45 G3: 141 ± 45 G4: 134 ± 39 Previous drug therapy, n (%): G1: 148 (50.5) G2: 146 (51.2) G3: 121 (56.5) G4: 117 (52.5) Percentage with poor efficacy, %: G1: 74 (50.0)** G2: 60 (41.1)** G3: 40 (33.1) G4: 46 (39.3) | Not able to hold urine upon experiencing urgency, %: G1: 11.3 G2: 21.1 G3: 15.9 G4: 25.6 G1/G2: P = 0.003 G3/G4: P = 0.007 No age-related difference Able to complete tasks before toilet visit in response to urgency,%: G1: 32.8 G2: 16.8 G3: 26.2 G4: 14.8 G1/G2: P = 0.001 G3/G4: P = 0.003 No age-related difference Incontinence episodes/week, mean ± SD G1: −12.0 ± 17.6 G2: −7.4 ± 15.6 G3: −11.5± 18.2 G4: −6.3 ± 15.0 G1/G2: P = 0.001 G3/G4: P < 0.001 No age-related difference Voids/day, mean ± SD G1: −2.0 ± 3.1 G2: −1.4 ± 3.1 G3: −1.4± 3.7 G4: −0.9 ± 2.6 G1/G2: P = 0.26 G3/G4: P = 0.92 Perception of bladder condition, improved, %: G1: 60.1 G2: 51.9 G3: 54.2 G4: 31.4 G1/G2: P < 0.05 G3/G4: P < 0.0001 Perception of bladder condition, no change, %: G1: 32.4 G2: 38.9 G3: 38.3 G4: 51.1 G4/G2: P < 0.0001 Perception of bladder condition, deterioration, %: G1: 7.2 G2: 9.1 G3: 7.5 G4: 17.5 Treatment beneficial, %: G1: 78.3 G2: 58.3 G3: 69.8 G4: 46.9 G1/G2: P = 0.001 G3/G4: P = 0.001 No age-related difference Voided volume (mL), mean ± SD: G1: 35 ± 53 G2: 13 ± 41 G3: 33± 47 G4: 16 ± 41 G1/G2: P < 0.001 G3/G4: P < 0.001 No age-related difference Adverse events, %: G1: 50.7 G2: 50.5 G3: 54.2 G4: 46.0 Dry mouth, severe, % G1–G2: 1.7 G3–G4: 1.9 Dry mouth, moderate, % G1–G2: 7.6 G3–G4: 6.5 Dry mouth, mild, % G1-G2: 13.4 G3-G4: 15.9 No dry mouth, % G1–G2: 77.3 G3–G4: 75.7 | Quality: Overall quality score: poor INTERNAL VALIDITY: poor Randomization: + Masking: + Pt selection criteria: + Loss to followup: + Drop-out rates: NR Power calculation: − Statistical issues: + EXTERNAL VALIDITY: fair Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: − Measurement methods: + Measurement reliability: + Intervention description: +
Author: Zinner et al., 2004 Country and setting: US, 51 sites Enrollment period: NR Funding: Indevus Corporation Author industry relationship disclosures: 4 of 5 Alza (1) Indevus (4) Kyowa (1) Lilly (2) Merck (1) Ortho-McNeil (1) Pfizer (2) Pharma (1) Pharmacia (1) Schwarz (1) Watson (2) Yamanouchi (1) | Design: RCT with 2 wk washout period Intervention: Trospium chloride vs placebo Groups: G1: Tropsium chloride 20 mg bid G2: placebo N at enrollment: G1: 262 G2: 261 N at follow-up: G1: 256 G2: 256 Women, n (%): G1: 203 (77.5) G2: 186 (71.3) Age, mean ± SD: G1: 63 ± 0.8 G2: 61.5 ± 0.8 Race/ethnicity, n (%): White: G1: 222 (84.7) G2: 225 (86.2) Black: G1: 26 (9.9) G2: 20 (7.7) Hispanic: G1: 10 (3.8) G2: 13 (5.0) Other: G1: 4 (1.6) G2: 3 (1.1) | Inclusion criteria: • Age ≥18 years • OAB symptoms ≥ 6 mos • Urinary urgency • ≥ 70 voids per week • ≥ 7 UUI episodes/week Exclusion criteria: • Stress predominant MUI • Insensate or overflow • Neurogenic bladder disorders • Significant renal disease • Hematuria hematuria and UTI at washout or ≥ twice in the prior year • BOO with PVR ≥ 100 mL • Concurrent use of any anticholinergic drug or other drug therapy for OAB within 21 days before randomization • Bladder surgery ≤ 6 mos • Bladder cancer • Interstitial cystitis • PSA ≥ 10 ng/mL • Diuretic use, estrogen therapy and nonmedical bladder therapy that was not part of a stable, long-term program. | UUI episodes/day, mean: G1: 3.9 G2: 4.3 Urgency episodes/day, mean: G1: 11.29 G2: 11.72 Urgency severity score, mean: G1: 1.8 G2: 1.8 Voids/day, mean: G1: 12.7 G2: 12.9 Daytime voids/day, mean: G1: 10.6 G2: 10.9 Nocturia episodes/day, mean: G1: 2.1 G2: 2.0 Voided volume (mL), mean: G1: 155.1 G2: 156.1 IIQ, mean score (SE): G1: 183.5 (5.6) G2: 195.4 (5.6) IIQ,, women only, mean score (SE): G1: 191.2 (6.3) G2: 201.9 (6.6) Incontinence Impact Questionnaire, travel subscale, score (SE): G1: 52.4 (1.7) G2: 55.6 (1.7) IIQ, social relationships, score (SE): G1: 37.8 (1.5) G2: 40.3 (1.5) IIQ, emotional health, mean score (SE): G1: 47.1 (1.6) G2: 49.6 (1.6) IIQ,, physical activity, mean score (SE): G1: 46.1 (1.6) G2: 50.2 (1.6) Prior OAB med, n (%): G1: 135 (51.5) G2: 142 (54.5) | UUI episodes/day, mean %change: G1: 59.0 G2: 44.2 G1/BL: P < 0.0001 Urgency episodes/day, mean change: G1: −0.22 G2: −1.08 G1/BL: P < 0.001 Urgency severity score, mean: G1: 1.8 G2: 1.8 Voids/day, mean change: G1: −2.37 G2: −1.29 G1/BL: P < 0.0001 Daytime voids/day, mean change: G1: −1.90 G2: −0.98 G1/BL: P < 0.0001 Nocturia episodes/day, mean change: G1: −0.47 G2: −0.29 G1/BL: P < 0.05 Voided volume (mL), mean change: G1: 32.1 G2: 7.7 G1/BL: P < 0.0001 IIQ,, LS mean change (SE): G1: −54.0 (5.6) G2: −36.0 (5.6) G1/BL: P ≤ 0.05 IIQ, women only, LS mean change (SE): G1: −59.1 (6.6) G2: −35.7 (6.9) G1/BL: P ≤ 0.05 IIQ, travel subscale, LS mean change (SE): G1: −14.9 (1.7) G2: −9.9 (1.7) G1/BL: P < ≤ 0.05 IIQ, social relationsips, LS mean change (SE): G1: −10.8 (1.4) G2: −6.3 (1.4) G1/BL: P ≤ 0.05 IIQ, emotional health, LS mean change (SE): G1: 14.1 (1.5) G2: −9.2 (1.5) G1/BL: P ≤ 0.05 IIQ, physical activity, LS mean change (SE): G1: −13.5 (1.7) G2: −11.0 (1.7) Dry mouth, n (%): G1: 57 (21.8) G2: 17 (6.5) Constipation, n (%): G1: 25 (9.5) G2: 10 (3.8) Headache, n (%): G1: 17 (6.5) G2: 12 (4.6) Diarrhea, n (%): G1: 8 (3.1) G2: 14 (5.4) Abdominal pain, n (%): G1: 8 (3.1) G2: 3 (1.1) Discontinuation due to AE, %: G1: 8.8 G2: 5.7 | Quality: Overall quality score: fair INTERNAL VALIDITY: fair Randomization: + Masking: − Pt selection criteria: + Loss to followup: ++ Drop-out rates: + Power calculation: − Statistical issues: + EXTERNAL VALIDITY: good Age: + Baseline OAB status: + Baseline characteristics: ++ Length of followup: + Measurement methods: + Measurement reliability: + Intervention description: +