# Appendix B Sample Data Abstract Forms

Systematic Review of the Etiology and Treatment of Overactive Bladder in Women

Abstract Review Form

First Author, Year: _________

Reference #_________ Abstractor Initials: ___ ___ ___

Primary Inclusion/Exclusion Criteria
1. Applies to SER topic (If not, select at least one of the following reasons):; a. ___Not OAB (including post-operative/iatrogenic); b. ___Stress or mixed incontinence; c. ___Isolated nocturia; d. ___Interstitial cystitis/painful bladder syndrome; e. ___Pelvic organ prolapse; f. ___Neurogenic conditions; g. ___Basic science or anatomy only; h. ___Imaging/diagnostic study only; i. ___Other__________ | Yes | No | Cannot Determine
2. Original research (exclude editorials, commentaries, letters to editor, reviews, etc) | Yes | No | Cannot Determine
3. Study published in English | Yes | No
4. Adult female study population (or includes women) | Yes | No | Cannot Determine
5. Ambulatory population (exclude if exclusively institutionalized or home-bound) | Yes | No
6. Eligible Study type; a. ___RCT; b. ___Cohorts with comparison; c. ___Case-control; d. ___Case series; e. ___Incidence/prevalence in representative populations; f. ___Cost of treatment in US populations (monetary & non-monetary) | Yes | No | Cannot Determine
7. Eligible study size Record N if < 50 relevant subjects enrolled: __________ | Yes | No | Cannot Determine

OAB is operationalized as idiopathic urinary urgency and frequency

Retain for:

____BACKGROUND/DISCUSSION

____REVIEW OF REFERENCES

____Other__________

COMMENTS:

Systematic Review of the Treatment Alternatives of Overactive Bladder in Women

Full-text Review Form

First Author, Year: __________

Reference #__________

Abstractor Initials: ___ ___ ___

OAB is operationalized as idiopathic urinary urgency and frequency

Primary Inclusion/Exclusion Criteria
8. Applies to SER topic (If not, select at least one of the following reasons):; a. ___Not OAB (including post-operative/iatrogenic); b. ___Stress or mixed incontinence; c. ___Isolated nocturia; d. ___Interstitial cystitis/painful bladder syndrome; e. ___Pelvic organ prolapse; f. ___Neurogenic conditions; g. ___Basic science or anatomy only; h. ___Imaging/diagnostic study only; i. ___Other__________ | Yes | No
9. Original research (exclude editorials, commentaries, letters to editor, reviews, etc) | Yes | No
10. Study published in English | Yes | No
11. Adult female study population (or reports data by gender) If No, % female__________ | Yes | No
12. Ambulatory population (exclude if exclusively institutionalized or home-bound) | Yes | No
13. Eligible Study type; - g. ___RCT /CCT; - h. ___Cohorts with comparison; - i. ___Case-control; - j. ___Case series; - k. ___Incidence/Prevalence study (survey-based); - l. ___Cost benefit/utility/effectiveness study | Yes | No
14. Eligible study size Record N if < 50 relevant subjects enrolled: __________ | Yes | No
15. Does study address one of the following:; a. ___Treatment of OAB; b. ___Incidence/prevalence of OAB; c. ___Monetary costs of treatment; d. ___Non-monetary costs/harms of treatment | Yes | No

EXCLUDE IF AN ITEM IN A GRAY BOX IS SELECTED

Content Inventory
1. ___Treatment of women with symptoms of OAB; a. ___Pharmacologic; b. ___Surgical; i. ___Botox; ii. ___Central neuromodulation; ___Sacral; iii. ___Peripheral neuromodulation; ___Tibial; ___Pudendal; iv. ___Augmentation cystoplasty; v. ___Other__________; c. ___Behavioral/Physical Therapy; d. ___Complementary and alternative therapies; e. ___Other__________
2. Modification of outcomes by:; a. ___Age; b. ___Body habitus/BMI; c. ___Clinical presentation, physical exam findings, urodynamic findings, symptom cluster; d. ___Diabetes; e. ___Functional status; f. ___Hormone replacement therapy; g. ___Menopausal status; h. ___Parity/post-partum/route-of-delivery; i. ___Prior treatment; j. ___Race/ethnicity; k. ___Smoking; l. ___Hysterectomy; m. ___Other factors__________; Length of follow-up:__________

Retain for:

____BACKGROUND/DISCUSSION

____REVIEW OF REFERENCES

____Other__________

COMMENTS: