# Appendix A Exact Search Strings

PubMed search strategies (last updated October 1, 2008)

| Search terms | Search results
#1 | (“Urinary Bladder, Overactive” [Mh] OR “overactive bladder” OR “urge incontinence” OR urinary incontinence, urge[mh] OR “detrusor instability” OR “overactive detrusor” OR “urinary urgency” OR “urinary frequency” OR “irritable bladder” OR “detrusor overactivity”) AND “female” [MeSH Terms] AND “humans” [MeSH Terms] AND English[lang] | 2886
#2 | #1 AND editorial[pt] | 10
#3 | #1 AND letter[pt] | 30
#4 | #1 AND case reports[pt] | 164
#5 | #1 AND review[pt] | 299
#6 | #1 AND practice guideline[pt] | 2
#7 | #1 NOT (#2 OR #3 OR #4 OR #5 OR #6) | 2400^*,†^

* Approximately 250 of these citations represent pediatric literature (due to variability in indexing for this topic, we were unable to exclude pediatric literature at the search strategy level).

† Numbers do not total due to exclusions in more than one category; 5 items were indexed as both letters and case reports and 14 items were indexed as both reviews and case reports

EMBASE search (OVID) (last updated October 1, 2008)

| Search Terms | Search Results
#1 | * overactive bladder/ or * urinary urgency/ or * urge incontinence/ or * urinary frequency/ or * detrusor dyssynergia/ or * bladder irritation/ | 1624
#2 | limit 1 to (human and female and english language and (adult <18 to 64 years> or aged <65+ years>)) | 363
#3 | #2 and review.pt. | 12
#4 | #2 and conference paper.pt. | 4
#5 | #2 and editorial.pt. | 1
#6 | #2 and letter.pt. | 0
#7 | #2 and note.pt. | 3
#8 | #2 and short survey.pt. | 4
#9 | #2 and case report/ | 18
#10 | #2 and practice guideline/ | 4
#11 | #2 and “systematic review”/ | 1
#12 | #2 and meta analysis/ | 1
#13 | #2 not (3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12) | 318^*,†^

* Overlap with PubMed: 310 citations; 8 new citations retrieved for inclusion.

† Numbers do not total due to exclusions in more than one category: 1 item was indexed as both a case report and review; 1 item was indexed as both a case report and a note; and 1 item was indexed as both a review and a systematic review.

CINAHL search (EBSCO) (last updated October 1, 2008)

| Search Terms | Search Results
#1 | (MH “Urge Incontinence”) or (MH “Overactive Bladder”) or “overactive bladder” or “urge incontinence” or “urge urinary incontinence” or “detrusor instability” or “overactive detrusor” or “urinary urgency” or “urinary frequency” or “detrusor overactivity”) and (MH “Adult+”) and (ZL “ENGLISH”) and (PT “Journal Article”) | 305
#2 | #1 and case reports | 18
#3 | #1 and review | 6
#4 | #1 and CE material | 5
#5 | #1 and abstract/commentary | 7
#6 | #1 and consumer literature | 5
#7 | 1 not (2 or 3 or 4 or 5 or 6) | 264^*^

* Overlap with PubMed: 240 citations; 24 new citations retrieved for inclusion.