# List of Acronyms/Abbreviations

±: plus or minus
≤: less than or equal to
≥: greater than or equal to
AE: adverse events
AHCPR: Agency for Health Care Policy and Research
AHRQ: Agency for Healthcare Research and Quality
AUC: area under the curve
AUM: ambulatory urodynamic monitoring
avg.: average
BAPFMT: biofeedback-assisted pelvic floor muscle training
BFQ: Bladder Function Questionnaire
b.i.d.: twice a day
BL: baseline
BM: bowel movements
BMI: body mass index
BOO: bladder outlet obstruction
BPH: benign prostatic hyperplasia
bpm: beats per minute
BRD: bladder retraining drill
BT: bladder training
CEE: Conjugated equine estrogens
CHF: Congestive heart failure
CI: confidence interval(s)
cm: centimeter
cmH2O: centimeters of water
CR: controlled release
CS: cognitive strategies
CT: combination therapy
CUBS: Compromised urinary bladder syndrome
d: day
d/t: drug treatment
DI: Detrusor instability
dL: deciliter
DM: Diabetes mellitus
DO: detrusor overactivity
Dx: diagnosis
EKG: electrocardiogram
ER: extended release
ES: electrical stimulation (electrostimulation)
etc.: et cetera
EtOH: Ethanol (alcohol)
F: F-distribution
G: group
GI: gastrointestinal
GII: global impression of improvement
GSI: genuine stress incontinence
GU: genitourinary
HAD: Hospital Anxiety and Depression Scale
H_2_O: water
hr(s): hour(s)
HRQoL: Health related quality of life
HRT: hormone replacement therapy
Hx: history
Hz: hertz
IBD: irritable bowel disease
IC: interstitial cystitis
ICIQ: International Consultation on Incontinence Modular Questionnaire
ICIQ-SF: International Consultation on Incontinence Questionnaire-Short Form
IIQ: Incontinence Impact Questionnaire
IIQ-R: Incontinence Impact Questionnaire-Revised
IMPACT: Improvement in Patients: Assessing symptomatic control with tolterodine
IQR: interquartile range
IR: immediate release
ITT: intention to treat
IUSS: Indevus Urgency Severity Scale
KQ: key question
kg/m^2^: kilograms per meter squared
KHQ: King’s Health Questionnaire
L: liter
LCB: low-compliance bladder
LOCF: last observation carried forward
LOS: length of stay
LS: least square
Ltd: limited
LTFU: Loss to followup
LUT: Lower urinary tract
LUTS: Lower urinary tract syndrome
mg: milligram
min: minute(s)
mL: milliliter
mL/s: milliliters per second
mm: millimeter
MMSE: Mini Mental Status Exam
mo(s): month(s)
MUI: Mixed urinary incontinence
MVV: Mean volume voided
n, N: number
ng: nanogram
NIH: National Institutes of Health
NR: not reported
NS: Not significant
OAB: Overactive bladder
OAB-q: OAB questionnaire
OAB-SCS: OAB-Symptom Composite Score
OCAS: oral controlled absorption system
P, p: p value
PFME: pelvic floor muscle exercises
PFMT: pelvic floor muscle training
PGA: patient-reported goal achievement
PISQ: Pelvic Organ Prolapse/Urinary Incontinence Sexual Questionnaire
PME: pelvic muscle exercises
PNN50: measure of heart rate variability
P.O.: per oral (by mouth)
PPBC: Patient perception of bladder condition
PPBCS: Patient perception of bladder condition scale
PPIUS: Patient Perception of Intensity of Urgency Scale
PPPY: per person per year
PRO: Patient reported outcome(s)
Pt: patient
PVR: post-void residual
qAM: every morning
qd: every day
qid: four times per day
QoL: quality of life
QTcB: QT interval correct for heart rate using Bazett’s formula
RCT: randomized controlled trial
RTX: resiniferatoxin
s: second
SCL-90-R: Symptom Checklist-90-Revised
SD: standard deviation
SE: standard error
SF: Sexual function
sec: second
SNM: sacroneuromodulation
SQoL-F: Sexual Quality of Life Questionnaire-Female
subj.: subjects
SUI: Stress urinary incontinence
Sx: symptoms
t.i.d.: three times a day
TDS: transdermal delivery system
UDI: Urogenital Distress Inventory
UDS: urodynamics
UFICQ: Urinary Frequency and Incontinence Questionnaire
UI: urinary incontinence
US: United States
UTI: urinary tract infection
UUDI: Urge Urogenital Distress Inventory
UUI: Urge urinary incontinence
VAS: visual analog scale
vs., v: versus
w/: with
wk(s): week(s)
x: times
yr(s): year(s)