# Acknowledgments

We are indebted to a tireless group of colleagues who made this report possible. Each step of systematic reviews draws on the skills and attention of an entire team.

Dr. Shilpa Amin has been an insightful task order officer who brought special considerations and decisions into focus. She was patient with our many questions, created a strong link with our project partner, and provided practical advice as we tackled challenges.

Ms. Rachel Bazan was our energetic student worker. She spent hours helping to track and file documents, always positive, and always ready to ensure that the project investigators had what they needed to do their work.

Dr. Liana Castel served as a quality grader and brought to the project her expertise in study design and analytic methods. We thank her for her thoughtful attention to the process of quality grading and willingness to help. Her comments on approaches to study reporting, particularly as they related to the implications of loss to followup and drop out, were especially valued.

Ms. Allison Glasser provided research assistance on this report, including combing papers for specific data points requested by the investigators and formatting summary and evidence tables. We appreciate her eagerness to learn and employ systematic review methods and her commitment to ensuring that tables were formatted exactly to specification. Ms. Glasser demonstrated great flexibility under pressure filling many needs.

Dr. Mark Hartmann brought his extraordinary attention to detail – and his commitment to perfection – to completion of the evidence tables. He spent many, many hours checking and rechecking tables both for formatting and for content. His ability to point out inconsistencies and enhance uniformity was key to ensuring smooth development of the evidence tables.

Ms. Sarah McLellan was a source of energy for all as she enthusiastically went about formatting evidence tables and completing and organizing appendices. We are grateful to lean on such detail oriented and focused research staff with a gift for encouraging others.

Ms. Toye Spencer oversaw the completion and formatting of the summary tables, and other critical elements of the report as a whole. She transferred data from investigator-developed spreadsheets into more tables than we imagined – and made sure that formatting was consistent, keeping track of the innumerable sets of changes that came her way.

Ms. Rachel Walden is a key member of the library science staff – her support of Ms. Jerome, including her creative insights and detailed approach to literature searching was invaluable. Her thoughtful attention to detail in reviewing abstracts and articles for inclusion in the review was a generous gift to the project and to the EPC as a whole.