# Reference List

1 Yoon PW, Scheuner MT, Peterson-Oehlke KL, et al. Can family history be used as a tool for public health and preventive medicine?. Genet Med. 2002;4(4):304-10. [pmid: 12172397].
2 Melbostad E, Eduard W, Magnus P. Determinants of asthma in a farming population. Scand J Work Environ Health. 1998;24(4):262-9. [pmid: 9754857].
3 Cauley JA, Song J, Dowsett SA, et al. Risk factors for breast cancer in older women: The relative contribution of bone mineral density and other established risk factors. Breast Cancer Res Treat. 2007;102(2):181-8. [pmid: 17028986].
4 Halapy E, Chiarelli AM, Klar N, et al. Accuracy of breast screening among women with and without a family history of breast and/or ovarian cancer. Breast Cancer Res Treat. 2005;90(3):299-305. [pmid: 15830144].
5 Denic S, Bener A. Consanguinity decreases risk of breast cancer--cervical cancer unaffected. Br J Cancer. 2001;85(11):1675-9. [pmid: 11742487].
6 Kerlikowske K, Barclay J, Grady D, et al. Comparison of risk factors for ductal carcinoma in situ and invasive breast cancer. J Natl Cancer Inst. 1997;89(1):76-82. [pmid: 8978410].
7 Wei EK, Giovannucci E, Wu K, et al. Comparison of risk factors for colon and rectal cancer. Int J Cancer. 2004;108(3):433-42. [pmid: 14648711].
8 Sandhu MS, Luben R, Khaw KT. Prevalence and family history of colorectal cancer: implications for screening. J Med Screen. 2001;8(2):69-72. [pmid: 11480446].
9 Byeon J-S, Yang S-K, Kim TI, et al. Colorectal neoplasm in asymptomatic Asians: a prospective multinational multicenter colonoscopy survey. Gastrointest Endosc. 2007;65(7):1015-22. [pmid: 17531636].
10 Rodriguez C, Calle EE, Miracle-McMahill HL, et al. Family history and risk of fatal prostate cancer. Epidemiology. 1997;8(6):653-7. [pmid: 9345665].
11 Ahn J, Moslehi R, Weinstein SJ, et al. Family history of prostate cancer and prostate cancer risk in the Alpha-Tocopherol, Beta-Carotene Cancer Prevention (ATBC) Study. Int J Cancer. 2008;123(5):1154-9. [pmid: 18546266].
12 Cerhan JR, Parker AS, Putnam SD, et al. Family history and prostate cancer risk in a population-based cohort of Iowa men. Cancer Epidemiology Biomarkers & Prevention. 1999;8(1):53-60.
13 Chen Y-C, Page JH, Chen R, et al. Family history of prostate and breast cancer and the risk of prostate cancer in the PSA era. Prostate. 2008;68(14):1582-91. [pmid: 18646000].
14 Makinen T, Tammela TL, Stenman UH, et al. Family history and prostate cancer screening with prostate-specific antigen. J Clin Oncol. 2002;20(11):2658-63. [pmid: 12039927].
15 Kalish LA, McDougal WS, McKinlay JB. Family history and the risk of prostate cancer. Urology. 2000;56(5):803-6. [pmid: 11068306].
16 Sesso HD, Lee IM, Gaziano JM, et al. Maternal and paternal history of myocardial infarction and risk of cardiovascular disease in men and women. Circulation. 2001;104(4):393-8. [pmid: 11468199].
17 Piros S, Karlehagen S, Lappas G, et al. Risk factors for myocardial infarction among Swedish railway engine drivers during 10 years follow-up. J Cardiovasc Risk. 2000;7(5):395-400. [pmid: 11143770].
18 Jousilahti P, Puska P, Vartiainen E, et al. Parental history of premature coronary heart disease: an independent risk factor of myocardial infarction. J Clin Epidemiol. 1996;49(5):497-503. [pmid: 8636722].
19 Hippe M, Vestbo J, Hein HO, et al. Familial predisposition and susceptibility to the effect of other risk factors for myocardial infarction. J Epidemiol Community Health. 1999;53(5):269-76. [pmid: 10396532].
20 Djousse L, Gaziano JM. Parental history of myocardial infarction and risk of heart failure in male physicians. Eur J Clin Invest. 2008;38(12):896-901. [pmid: 19021713].
21 Dodani S, MacLean DD, LaPorte RE, et al. Distribution and determinants of coronary artery disease in an urban Pakistani setting.[erratum appears in Ethn Dis. 2006 Winter;16(1):309 Note: MacLean, David D [added]; LaPorte, Ronald E [added]; Joffres, Michel [added]]. Ethnicity & Disease. 2005;15(3):429-35. [pmid: 16108303].
22 Scheuner MT, Whitworth WC, McGruder H, et al. Expanding the definition of a positive family history for early-onset coronary heart disease. Genetic Medicine. 2006;8(8):491-501.
23 Magno CP, Araneta MR, Macera CA, et al. Cardiovascular disease prevalence, associated risk factors, and plasma adiponectin levels among Filipino American women.[summary for patients in Ethn Dis. 2008 Autumn;18(4):524; PMID: 19157264]. Ethnicity & Disease. 2008;18(4):458-63. [pmid: 19157250].
24 Morrison AC, Fornage M, Liao D, et al. Parental history of stroke predicts subclinical but not clinical stroke: the Atherosclerosis Risk in Communities Study. Stroke. 2000;31(9):2098-102. [pmid: 10978036].
25 Jousilahti P, Rastenyte D, Tuomilehto J, et al. Parental history of cardiovascular disease and risk of stroke. A prospective follow-up of 14371 middle-aged men and women in Finland. Stroke. 1997;28(7):1361-6. [pmid: 9227684].
26 Kadota A, Okamura T, Hozawa A, et al. Relationships between family histories of stroke and of hypertension and stroke mortality: NIPPON DATA80, 1980–1999. Hypertension Research - Clinical & Experimental. 2008;31(8):1525-31.
27 Bjornholt JV, Erikssen G, Liestol K, et al. Type 2 diabetes and maternal family history: an impact beyond slow glucose removal rate and fasting hyperglycemia in low-risk individuals? Results from 22.5 years of follow-up of healthy nondiabetic men. Diabetes Care. 2000;23(9):1255-9. [pmid: 10977015].
28 Boer JM, Feskens EJ, Kromhout D. Characteristics of non-insulin-dependent diabetes mellitus in elderly men: effect modification by family history. Int J Epidemiol. 1996;25(2):394-402. [pmid: 9119566].
29 Nakanishi S, Yamane K, Kamei N, et al. Relationship between development of diabetes and family history by gender in Japanese-Americans. Diabetes Res Clin Pract. 2003;61(2):109-15. [pmid: 12951279].
30 Rahman M, Simmons RK, Harding AH, et al. A simple risk score identifies individuals at high risk of developing type 2 diabetes: A prospective cohort study. Fam Pract. 2008;25(3):191-6. [pmid: 18515811].
31 Meigs JB, Cupples LA, Wilson PW. Parental transmission of type 2 diabetes: the Framingham Offspring Study. Diabetes. 2000;49(12):2201-7. [pmid: 11118026].
32 Mohan V, Shanthirani CS, Deepa R. Glucose intolerance (diabetes and IGT) in a selected South Indian population with special reference to family history, obesity and lifestyle factors--the Chennai Urban Population Study (CUPS 14). Journal of Association of Physicians of India. 2003;51:771-7. [pmid: 14651136].
33 Ebbesson SOK, Schraer CD, Risica PM, et al. Diabetes and impaired glucose tolerance in three Alaskan eskimo populations: The Alaska-Siberia project. Diabetes Care. 1998;21(4):563-9. [pmid: 9571343].
34 Nyenwe EA, Odia OJ, Ihekwaba AE, et al. Type 2 diabetes in adult Nigerians: A study of its prevalence and risk factors in Port Harcourt, Nigeria. Diabetes Res Clin Pract. 2003;62(3):177-85. [pmid: 14625132].
35 Haron Y, Hussein O, Epstein L, et al. Type 2 diabetes among Circassians in Israel. Israel Medical Association Journal. 2006;8(9):622-6. [pmid: 17058413].
36 Gikas A, Sotiropoulos A, Panagiotakos D, et al. Prevalence, and associated risk factors, of self-reported diabetes mellitus in a sample of adult urban population in Greece: MEDICAL Exit Poll Research in Salamis (MEDICAL EXPRESS 2002). BMC Public Health. 2004;4:1-9. [pmid: 14706119].
37 Hariri S, Yoon PW, Qureshi N, et al. Family history of type 2 diabetes: a population-based screening tool for prevention?. Genetic Medicine. 2006;8(2):102-8.
38 Carlsson S, Midthjell K, Grill V. Influence of family history of diabetes on incidence and prevalence of latent autoimmune diabetes of the adult: results from the Nord-Trondelag Health Study. Diabetes Care. 2007;30(12):3040-5. [pmid: 17878245].
39 Hilding A, Eriksson AK, Agardh EE, et al. The impact of family history of diabetes and lifestyle factors on abnormal glucose regulation in middle-aged Swedish men and women. Diabetologia. 2006;49(11):2589-98. [pmid: 16969647].
40 Annis AM, Caulder MS, Cook ML, et al. Family history, diabetes, and other demographic and risk factors among participants of the National Health and Nutrition Examination Survey 1999–2002. Preventing Chronic Disease. 2005;2(2):A19. [pmid: 15888230].
41 Bindraban NR, Van Valkengoed IGM, Mairuhu G, et al. Prevalence of diabetes mellitus and the performance of a risk score among Hindustani Surinamese, African Surinamese and ethnic Dutch: A cross-sectional population-based study. BMC Public Health. 2008;8:2008. Article Number: 271. Date of Publication: 2008.
42 Shera AS, Jawad F, Maqsood A. Prevalence of diabetes in Pakistan. Diabetes Res Clin Pract. 2007;76(2):219-22. [pmid: 17005289].
43 Ajlouni K, Khader YS, Batieha A, et al. An increase in prevalence of diabetes mellitus in Jordan over 10 years. J Diabetes Complications. 2008;22(5):317-24. [pmid: 18413210].
44 Tariq SM, Matthews SM, Hakim EA, et al. The prevalence of and risk factors for atopy in early childhood: A whole population birth cohort study. J Allergy Clin Immunol. 1998;101(5):587-93. [pmid: 9600493].
45 Pohlabeln H, Jacobs S, Bohmann J. Exposure to pets and the risk of allergic symptoms during the first 2 years of life. J Investig Allergol Clin Immunol. 2007;17(5):302-8.
46 Bergmann RL, Edenharter G, Bergmann KE, et al. Predictability of early atopy by cord blood-IgE and parental history. Clin Exp Allergy. 1997;27(7):752-60. [pmid: 9249267].
47 Kulig M, Bergmann R, Edenharter G, et al. Does allergy in parents depend on allergy in their children? Recall bias in parental questioning of atopic diseases. Multicenter Allergy Study Group. Journal of Allergy & Clinical Immunology. 2000;105(2:Pt 1):t-8.
48 Lopez N, Barros-Mazon S, Vilela MM, et al. Genetic and environmental influences on atopic immune response in early life. Journal of Investigational Allergology & Clinical Immunology. 1999;9(6):392-8. [pmid: 10664935].
49 London SJ, Gauderman WJ, Avol E, et al. Family history and the risk of early-onset persistent, early-onset transient, and late-onset asthma. Epidemiology. 2001;12(5):577-83. [pmid: 11505179].
50 Garcia-Marcos L, Castro-Rodriguez JA, Suarez-Varela MM, et al. A different pattern of risk factors for atopic and non-atopic wheezing in 9–12-year-old children. Pediatric Allergy & Immunology. 2005;16(6):471-7. [pmid: 16176393].
51 Bener A, Janahi IA, Sabbah A. Genetics and environmental risk factors associated with asthma in schoolchildren. Allerg Immunol (Paris). 2005;37(5):163-8.
52 Alford SH, Zoratti E, Peterson EL, et al. Parental history of atopic disease: disease pattern and risk of pediatric atopy in offspring.[see comment]. Journal of Allergy & Clinical Immunology. 2004;114(5):1046-50. [pmid: 15536408].
53 Montnemery P, Lanke J, Lindholm LH, et al. Familial related risk-factors in the development of chronic bronchitis/emphysema as compared to asthma assessed in a postal survey. Eur J Epidemiol. 2000;16(11):1003-7. [pmid: 11421467].
54 Hu FB, Persky V, Flay BR, et al. An epidemiological study of asthma prevalence and related factors among young adults. J Asthma. 1997;34(1):67-76. [pmid: 9033442].
55 Ones U, Sapan N, Somer A, et al. Prevalence of childhood asthma in Istanbul, Turkey. Allergy. 1997;52(5):570-5. [pmid: 9201370].
56 Sugiyama T, Sugiyama K, Toda M, et al. Risk factors for asthma and allergic diseases among 13–14-year-old schoolchildren in Japan. Allergology International. 2002;51(2):139-50.
57 Patrzalek M, Najberg E, Piontek E. The effect of chosen environmental factors and family predisposition to atopy in the development of allergic diseases in children. International Review of Allergology and Clinical Immunology. 2003;9(4):179-84.
58 Chatkin MN, Menezes AMB, Victora CG, et al. High prevalence of asthma in preschool children in southern Brazil: A population-based study. Pediatr Pulmonol. 2003;35(4):296-301. [pmid: 12629628].
59 Chatkin MN, Menezes AMB. Prevalence and risk factors for asthma in schoolchildren in southern Brazil. J Pediatr (Rio J). 2005;81(5):411-6. [pmid: 16247545].
60 Weissman MM, Wickramaratne P, Nomura Y, et al. Families at high and low risk for depression: a 3-generation study. Arch Gen Psychiatry. 2005;62(1):29-36. [pmid: 15630070].
61 Warner V, Wickramaratne P, Weissman MM. The role of fear and anxiety in the familial risk for major depression: a three-generation study. Psychol Med. 2008;38(11):1543-56. [pmid: 18275630].
62 Reinherz HZ, Paradis AD, Giaconia RM, et al. Childhood and adolescent predictors of major depression in the transition to adulthood. The American Journal of Psychiatry. 2003;160(12):2141-7. [pmid: 14638584].
63 Hariri S, Yoon PW, Moonesinghe R, et al. Evaluation of family history as a risk factor and screening tool for detecting undiagnosed diabetes in a nationally representative survey population. Genetic Medicine. 2006;8(12):752-9.
64 Melidonis AM, Tournis SM, Kompoti MK, et al. Increased prevalence of diabetes mellitus in a rural Greek population. Rural Remote Health. 2006;6(1):534. [pmid: 16579675].
65 Jorgensen ME, Bjeregaard P, Borch-Johnsen K, et al. Diabetes and impaired glucose tolerance among the inuit population of greenland. Diabetes Care. 2002;25(10):1766-71. [pmid: 12351475].
66 Saquib N, Kritz-Silverstein D, Barrett-Connor E. Age at menarche, abnormal glucose tolerance and type 2 diabetes mellitus: The Rancho Bernardo Study. Climacteric. 2005;8(1):76-82. [pmid: 15804735].
67 Ozdemir L, Topcu S, Nadir I, et al. The prevalence of diabetes and impaired glucose tolerance in Sivas, Central Anatolia, Turkey. Diabetes Care. 2005;28(4):795-8. [pmid: 15793175].
68 Levitt NS, Steyn K, Lambert EV, et al. Modifiable risk factors for Type 2 diabetes mellitus in a peri-urban community in South Africa. Diabet Med. 1999;16(11):946-50. [pmid: 10588525].
69 Park Y, Lee H, Koh C-S, et al. Prevalence of diabetes and IGT in Yonchon County, South Korea. Diabetes Care. 1995;18(4):545-8. [pmid: 7497867].
70 Hennis A, Wu S-Y, Nemesure B, et al. Diabetes in a Carribean population: Epidemiological profile and implications. Int J Epidemiol. 2002;31(1):234-9. [pmid: 11914326].
71 Chhabra SK, Gupta CK, Chhabra P, et al. Prevalence of bronchial asthma in schoolchildren in Delhi. J Asthma. 1998;35(3):291-6. [pmid: 9661682].
72 Sugimori H, Miyakawa M, Yoshida K, et al. Health risk assessment for diabetes mellitus based on longitudinal analysis of MHTS database. J Med Syst. 1998;22(1):27-32. [pmid: 9554107].
73 Kim C-H, Park J-Y, Lee K-U, et al. Fatty liver is an independent risk factor for the development of type 2 diabetes in Korean adults. Diabet Med. 2008;25(4):476-81. [pmid: 18346164].
74 Hedlund U, Ronmark E, Eriksson K, et al. Occupational exposure to dust, gases and fumes, a family history of asthma and impaired respiratory health. Scandinavian Journal of Work, Environment & Health. 2008;34(5):381-6.
75 Enriquez R, Addington W, Davis F, et al. The relationship between vaccine refusal and self-report of atopic disease in children. Journal of Allergy & Clinical Immunology. 2005;115(4):737-44. [pmid: 15805992].
76 Krakowiak A, Krawczyk P, Szulc B, et al. Prevalence and host determinants of occupational bronchial asthma in animal shelter workers. Int Arch Occup Environ Health. 2007;80(5):423-32. [pmid: 17021841].
77 Hedlund U, Eriksson K, Ronmark E. Socioeconomic status is related to incidence of asthma and respiratory symptoms in adults. Eur Respir J. 2006;28(2):303-10. [pmid: 16540503].
78 Khan S, Roy A, Christopher DJ, et al. Prevalence of bronchial asthma among bank employees of Vellore using questionnaire-based data. J Indian Med Assoc. 2002;100(11):643-4+655. [pmid: 12797634].
79 Boskabady MH, Kolahdoz GH. Prevalence of asthma symptoms among the adult population in the city of Mashhad (north-east of Iran). Respirology. 2002;7(3):267-72. [pmid: 12153693].
80 Tariq SM, Stevens M, Matthews S, et al. Cohort study of peanut and tree nut sensitisation by age of 4 years. Br Med J. 1996;313(7056):514-7. [pmid: 8789974].
81 Heldgaard PE, Griffin SJ. Routinely collected general practice data aids identification of people with hyperglycaemia and metabolic syndrome. Diabet Med. 2006;23(9):996-1002. [pmid: 16922706].
82 Kalyoncu AF, Demir AU, Ozcakar B, et al. Asthma and allergy in Turkish university students: Two cross-sectional surveys 5 years apart. Allergol Immunopathol (Madr). 2001;29(6):264-71. [pmid: 11834185].
83 Sellers TA, Mink PJ, Cerhan JR, et al. The role of hormone replacement therapy in the risk for breast cancer and total mortality in women with a family history of breast cancer.[see comment]. Ann Intern Med. 1997;127(11):973-80. [pmid: 9412302].
84 Granstrom C, Sundquist J, Hemminki K. Population attributable risks for breast cancer in Swedish women by morphological type. Breast Cancer Research & Treatment. 2008;111(3):559-68. [pmid: 17990099].
85 Motala AA, Esterhuizen T, Gouws E, et al. Diabetes and other disorders of glycemia in a rural South African community: prevalence and associated risk factors. Diabetes Care. 2008;31(9):1783-8. [pmid: 18523142].
86 Tan JT, Tan LSM, Chia KS, et al. A family history of type 2 diabetes is associated with glucose intolerance and obesity-related traits with evidence of excess maternal transmission for obesity-related traits in a South East Asian population. Diabetes Res Clin Pract. 2008;82(2):268-75. [pmid: 18804306].
87 Kurukulaaratchy RJ, Fenn M, Matthews S, et al. Characterisation of atopic and non-atopic wheeze in 10 year old children. Thorax. 2004;59(7):563-8. [pmid: 15223861].
88 Gillespie J, Wickens K, Siebers R, et al. Endotoxin exposure, wheezing, and rash in infancy in a New Zealand birth cohort. J Allergy Clin Immunol. 2006;118(6):1265-70. [pmid: 17157655].
89 Lack G, Fox D, Northstone K, et al. Factors associated with the development of peanut allergy in childhood. N Engl J Med. 2003;348(11):977-85. [pmid: 12637607].
90 Dotterud LK, Kvammen B, Lund E, et al. Prevalence and some clinical aspects of atopic dermatitis in the community of Sor-Varanger. Acta Derm Venereol. 1995;75(1):50-3. [pmid: 7747535].
91 Parent ME, Ghadirian P, Lacroix A, et al. Accuracy of reports of familial breast cancer in a case-control series. Epidemiology. 1995;6(2):184-6. [pmid: 7742408].
92 Eerola H, Blomqvist C, Pukkala E, et al. Familial breast cancer in southern Finland: how prevalent are breast cancer families and can we trust the family history reported by patients?. Eur J Cancer. 2000;36(9):1143-8. [pmid: 10854948].
93 Anton-Culver H, Kurosaki T, Taylor TH, et al. Validation of family history of breast cancer and identification of the BRCA1 and other syndromes using a population-based cancer registry. Genet Epidemiol. 1996;13(2):193-205. [pmid: 8722746].
94 Schneider KA, DiGianni LM, Patenaude AF, et al. Accuracy of cancer family histories: comparison of two breast cancer syndromes. Genetic Testing. 2004;8(3):222-8. [pmid: 15727243].
95 Kerber RA, Slattery ML. Comparison of self-reported and database-linked family history of cancer data in a case-control study. Am J Epidemiol. 1997;146(3):244-8. [pmid: 9247008].
96 Aitken J, Bain C, Ward M, et al. How accurate is self-reported family history of colorectal cancer?. Am J Epidemiol. 1995;141(9):863-71. [pmid: 7717363].
97 Mitchell RJ, Brewster D, Campbell H, et al. Accuracy of reporting of family history of colorectal cancer. Gut - an international journal of gastroenterology and hepatology. 2004;53(2):291-5.
98 Zhu K, McKnight B, Stergachis A, et al. Comparison of self report data and medical records data: Results from a case control study on prostate cancer. Int J Epidemiol. 1999;28(3):409-17. [pmid: 10405842].
99 King TM, Tong L, Pack RJ, et al. Accuracy of family history of cancer as reported by men with prostate cancer. Urology. 2002;59(4):546-50. [pmid: 11927311].
100 Soegaard M, Jensen A, Frederiksen K, et al. Accuracy of self-reported family history of cancer in a large case-control study of ovarian cancer. Cancer Causes Control. 2008;19(5):469-79. [pmid: 18197461].
101 Ziogas A, Anton-Culver H. Validation of family history data in cancer family registries. Am J Prev Med. 2003;24(2):190-8. [pmid: 12568826].
102 Sijmons RH, Boonstra AE, Reefhuis J, et al. Accuracy of family history of cancer: clinical genetic implications. Eur J Hum Genet. 2000;8(3):181-6. [pmid: 10780783].
103 Novakovic B, Goldstein AM, Tucker MA. Validation of family history of cancer in deceased family members. J Natl Cancer Inst. 1996;88(20):1492-3. [pmid: 8841026].
104 Chang ET, Smedby KE, Hjalgrim H, et al. Reliability of self-reported family history of cancer in a large case-control study of lymphoma. J Natl Cancer Inst. 2006;98(1):61-8. [pmid: 16391372].
105 Aitken JF, Youl P, Green A, et al. Accuracy of case-reported family history of melanoma in Queensland, Australia. Melanoma Res. 1996;6(4):313-7. [pmid: 8873051].
106 Mussio P, Weber W, Brunetti D, et al. Taking a family history in cancer patients with a simple questionnaire. Anticancer Res. 1998;18(4B):2811-4. [pmid: 9713466].
107 Li G, Silverman JM, Smith CJ, et al. Validity of the family history method for identifying schizophrenia-related disorders. Psychiatry Res. 1997;70(1):39-48. [pmid: 9172275].
108 Fogelson DL, Nuechterlein KH, Asarnow RF, et al. Validity of the family history method for diagnosing schizophrenia, schizophrenia-related psychoses, and schizophrenia-spectrum personality disorders in first-degree relatives of schizophrenia probands. Schizophr Res. 2004;68(2–3):309-17. [pmid: 15099612].
109 Roy MA, Walsh D, Kendler KS. Accuracies and inaccuracies of the family history method: a multivariate approach. Acta Psychiatr Scand. 1996;93(4):224-34. [pmid: 8712019].
110 Heun R, Muller H. Interinformant reliability of family history information on psychiatric disorders in relatives. Eur Arch Psychiatry Clin Neurosci. 1998;248(2):104-9. [pmid: 9684920].
111 Heun R, Muller H, Papassotiropoulos A. Differential validity of informant-based diagnoses of dementia and depression in index subjects and in their first-degree relatives. Soc Psychiatry Psychiatr Epidemiol. 1998;33(10):510-3. [pmid: 9780815].
112 Heun R, Hardt J, Burkart M, et al. Validity of the family history method in relatives of gerontopsychiatric patients. Psychiatry Res. 1996;62(3):227-38. [pmid: 8804133].
113 Heun R, Maier W, Muller H. Subject and informant variables affecting family history diagnoses of depression and dementia. Psychiatry Res. 1997;71(3):175-80. [pmid: 9271790].
114 Weissman MM, Wickramaratne P, Adams P, et al. Brief screening for family psychiatric history: the family history screen. Arch Gen Psychiatry. 2000;57(7):675-82. [pmid: 10891038].
115 Lish JD, Weissman MM, Adams PB, et al. Family psychiatric screening instruments for epidemiologic studies: pilot testing and validation. Psychiatry Res. 1995;57(2):169-80. [pmid: 7480383].
116 Rougemont-Buecking A, Rothen S, Jeanpretre N, et al. Inter-informant agreement on diagnoses and prevalence estimates of anxiety disorders: Direct interview versus family history method. Psychiatry Res. 2008;157(1–3):211-23. [pmid: 17881063].
117 Ferro T, Klein DN. Family history assessment of personality disorders: I. Concordance with direct interview and between pairs of informants. J Personal Disord. 1997;11(2):123-36.
118 Reider CR, Halter CA, Castelluccio PF, et al. Reliability of reported age at onset for Parkinson’s disease. Mov Disord. 2003;18(3):275-9. [pmid: 12621630].
119 Marder K, Levy G, Louis ED, et al. Accuracy of family history data on Parkinson’s disease.[see comment]. Neurology. 2003;61(1):18-23. [pmid: 12847150].
120 Elbaz A, McDonnell SK, Maraganore DM, et al. Validity of family history data on PD: evidence for a family information bias.[see comment]. Neurology. 2003;61(1):11-7. [pmid: 12847149].
121 Bochud M, Burnier M, Paccaud F, et al. Patients’ sibling history was sensitive for hypertension and specific for diabetes. J Clin Epidemiol. 2004;57(5):497-501. [pmid: 15196620].
122 Karter AJ, Rowell SE, Ackerson LM, et al. Excess maternal transmission of type 2 diabetes: The Northern California Kaiser Permanente Diabetes Registry. Diabetes Care. 1999;22(6):938-43. [pmid: 10372246].
123 Murabito JM, Nam BH, D’Agostino RB Sr, et al. Accuracy of offspring reports of parental cardiovascular disease history: the Framingham Offspring Study.[see comment]. Ann Intern Med. 2004;140(6):434-40. [pmid: 15023709].
124 Bensen JT, Liese AD, Rushing JT, et al. Accuracy of proband reported family history: the NHLBI Family Heart Study (FHS). Genet Epidemiol. 1999;17(2):141-50. [pmid: 10414557].
125 Klungel OH, de Boer A, Paes AHP, et al. Cardiovascular diseases and risk factors in a population-based study in The Netherlands: Agreement between questionnaire information and medical records. Neth J Med. 1999;55(4):177-83. [pmid: 10555434].
126 France CR, Page GD. Assessing parental history of hypertension: father (and mother) knows best!. Psychophysiology. 1998;35(3):341-3. [pmid: 9564754].
127 Ankathil R, Jyothish B, Madhavan J, et al. Deficient DNA repair capacity: a predisposing factor and high risk predictive marker in familial colorectal cancer. Journal of Experimental & Clinical Cancer Research. 1999;18(1):33-7.
128 Silberberg JS, Wlodarczyk J, Fryer J, et al. Correction for biases in a population-based study of family history and coronary heart disease. The Newcastle Family History Study I. Am J Epidemiol. 1998;147(12):1123-32. [pmid: 9645790].
129 Kadison P, Pelletier EM, Mounib EL, et al. Improved screening for breast cancer associated with a telephone-based risk assessment. Prev Med. 1998;27(3):493-501. [pmid: 9612841].
130 Giles JT, Kennedy DT, Dunn EC, et al. Results of a community pharmacy-based breast cancer risk-assessment and education program. Pharmacotherapy. 2001;21(2):243-53. [pmid: 11213861].
131 Leggatt V, Mackay J, Marteau TM, et al. The psychological impact of a cancer family history questionnaire completed in general practice. J Med Genet. 2000;37(6):470-2. [pmid: 10928860].
132 Rose P, Humm E, Hey K, et al. Family history taking and genetic counselling in primary care. Fam Pract. 1999;16(1):78-83. [pmid: 10321401].
133 Qureshi N, Standen PJ, Hapgood R, et al. A randomized controlled trial to assess the psychological impact of a family history screening questionnaire in general practice. Fam Pract. 2001;18(1):78-83. [pmid: 11145633].
134 Volk LA, Staroselsky M, Newmark LP, et al. Do physicians take action on high risk family history information provided by patients outside of a clinic visit?. Medinfo. 2007;12(Pt:1):1-7.
135 Fletcher RH, Lobb R, Bauer MR, et al. Screening patients with a family history of colorectal cancer. J Gen Intern Med. 2007;22(4):508-13. [pmid: 17372801].
136 Murff HJ, Byrne D, Haas JS, et al. Race and family history assessment for breast cancer. J Gen Intern Med. 2005;20(1):75-80. [pmid: 15693932].
137 Acheson LS, Wiesner GL, Zyzanski SJ, et al. Family history-taking in community family practice: implications for genetic screening. Genet Med. 2000;2(3):180-5. [pmid: 11256663].
138 Karliner LS, Napoles-Springer A, Kerlikowske K, et al. Missed opportunities: family history and behavioral risk factors in breast cancer risk assessment among a multiethnic group of women. J Gen Intern Med. 2007;22(3):308-14. [pmid: 17356960].
139 Pinsky PF, Kramer BS, Reding D, et al. Reported family history of cancer in the prostate, lung, colorectal, and ovarian cancer screening trial. Am J Epidemiol. 2003;157(9):792-9. [pmid: 12727673].
140 Centers for Disease Control and Prevention. Chronic Disease Prevention and Health Promotion. National Center for Chronic Disease Prevention and Health Promotion. Chronic Disease Prevention and Health Promotion. http://www.cdc.gov/nccdphp/.
141 Kardia SLR, Modell SM, Peyser PA. Family-centered approaches to understanding and preventing coronary heart disease. Am J Prev Med. 2003;24(2):143-51. [pmid: 12568820].
142 Williams RR, Hunt SC, Heiss G, et al. Usefulness of cardiovascular family history data for population-based preventive medicine and medical research (the Health Family Tree Study and the NHLBI Family Heart Study). Am J Cardiol. 2001;87(2):129-35. [pmid: 11152826].
143 Hawe E, Talmud PJ, Miller GJ, et al. Family history is a coronary heart disease risk factor in the Second Northwick Park Heart Study. Ann Hum Genet. 2003;67(Pt:2):97-106. [pmid: 12675686].
144 Butterworth A. Family history as a risk factor for common, complex disease. Public Health Genetics Unit (now the PHG Foundation). Cambridge, U.K. 2007. www.phgfoundation.org/pages/family_history.htm.
145 Qureshi N, Wilson B, Santaguida P, et al. Collection and use of cancer family history in primary care. Evid Rep Technol Assess (Full Rep ). 2007;(159):1-84.
146 Reid GT, Walter FM, Brisbane JM, et al. Family history questionnaires designed for clinical use: a systematic review. Public Health Genomics. 2009;12(2):73-83. [pmid: 19039251].
147 Kardia SL, Modell SM, Peyser PA. Family-centered approaches to understanding and preventing coronary heart disease. [Review] [60 refs]. Am J Prev Med. 2003;24(2):143-51. [pmid: 12568820].
148 Burke W, Fesinmeyer M, Reed K, et al. Family history as a predictor of asthma risk. [Review] [67 refs]. Am J Prev Med. 2003;24(2):160-9. [pmid: 12568822].
149 Bennett R. Is a universal family history tool feasible?. The genetic family history in practice. Accessed July 2, 2008. www.nchpeg.org/newsletter/inpracticespr04.pdf.
150 Yoon PW, Scheuner MT, Khoury MJ. Research priorities for evaluating family history in the prevention of common chronic diseases. Am J Prev Med. 2003;24(2):128-35. [pmid: 12568818].
151 Hunt SC, Williams RR, Barlow GK. A comparison of positive family history definitions for defining risk of future disease. J Chronic Dis. 1986;39(10):809-21. [pmid: 3760109].
152 Rich EC, Burke W, Heaton CJ, et al. Reconsidering the family history in primary care. J Gen Intern Med. 2004;19(3):273-80. [pmid: 15009784].
153 Qureshi N, Kai J. Informing patients of familial diabetes mellitus risk: How do they respond? A cross-sectional survey. BMC Health Services Research. 2008;8:2008. Article Number: 37. Date of Publication: 2008.
154 Shah M, Zhu K, Palmer RC, et al. Breast, colorectal, and skin cancer screening practices and family history of cancer in U.S. women. Journal of Women’s Health. 2007;16(4):526-34.
155 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Current Controlled Trials. 1996;17(1):1-12.
156 Zamora J, Abraira V, Muriel A, et al. Meta-DisSc: a software for meta-analysis of test accuracy data. BMC Medical Research Methodology. 2006;6(31).
157 Horvath AR, Pewsner D. Systematic reviews in laboratory medicine: principles, processes and practical considerations. Clin Chim Acta. 2004;342(1–2):3-39.
158 Jacobsen PB, Lamonde LA, Honour M, et al. Relation of family history of prostate cancer to perceived vulnerability and screening behavior. Psychooncology. 2004;13(2):80-5. [pmid: 14872526].
159 de Luis DA, Sagrado MG, Aller R, et al. Influence of ALA54THR polymorphism of fatty acid-binding protein 2 on obesity and cardiovascular risk factors. Horm Metab Res. 2007;39(11):830-4. [pmid: 17992640].
160 Cappelli M, Surh L, Walker M, et al. Psychological and social predictors of decisions about genetic testing for breast cancer in high-risk women. Psychol Health Med. 2001;6(3):321-33.
161 Williams KP, Sheppard VB, Todem D, et al. Family matters in mammography screening among African-American women age [greater-than or equal to]40. J Natl Med Assoc. 2008;100(5):508-15. [pmid: 18507203].
162 Gil F, Mendez I, Sirgo A, et al. Perception of breast cancer risk and surveillance behaviours of women with family history of breast cancer: a brief report on a Spanish cohort. Psychooncology. 2003;12(8):821-7. [pmid: 14681955].
163 Helfand BT, Loeb S, Cashy J, et al. Tumor characteristics of carriers and noncarriers of the deCODE 8q24 prostate cancer susceptibility alleles. J Urol. 2202;179(6):2197-201. [pmid: 18423739].
164 Longacre AV, Cramer LD, Gross CP. Screening colonoscopy use among individuals at higher colorectal cancer risk. J Clin Gastroenterol. 2006;40(6):490-6. [pmid: 16825930].
165 Shah M, Zhu K, Palmer RC, et al. Family history of cancer and utilization of prostate, colorectal and skin cancer screening tests in U.S. men. Prev Med. 2007;44(5):459-64. [pmid: 17320159].
166 Petrisek A, Campbell S, Laliberte L. Family history of breast cancer: impact on the disease experience. Cancer Pract. 2000;8(3):135-42. [pmid: 11898138].
167 Madlensky L, Flatt SW, Bardwell WA, et al. Is family history related to preventive health behaviors and medical management in breast cancer patients?. Breast Cancer Res Treat. 2005;90(1):47-54. [pmid: 15770526].
168 Andersen MR, Peacock S, Nelson J, et al. Worry about ovarian cancer risk and use of ovarian cancer screening by women at risk for ovarian cancer.[see comment]. Gynecol Oncol. 2002;85(1):3-8. [pmid: 11925113].
169 Bloom JR, Stewart SL, Oakley-Girvans I, et al. Family history, perceived risk, and prostate cancer screening among African American men. Cancer Epidemiology Biomarkers & Prevention. 2006;15(11):2167-73.
170 Cotter MP, Gern RW, Ho GY, et al. Role of family history and ethnicity on the mode and age of prostate cancer presentation. Prostate. 2002;50(4):216-21. [pmid: 11870799].
171 Bennett RL. The practical guide to the genetic family history. New York. John Wiley. 1999.
172 Wattendorf DJ, Hadley DW. Family history: The three-generation pedigree. Am Fam Physician. 2005;72(3):441-8. [pmid: 16100858].
173 Silberberg J, Fryer J, Wlodarczyk J, et al. Comparison of family history measures used to identify high risk of coronary heart disease. Genet Epidemiol. 1999;16(4):344-55. [pmid: 10207716].
174 Jankovic J, Beach J, Ashizawa T. Emotional and functional impact of DNA testing on patients with symptoms of Huntington’s disease. J Med Genet. 1995;32(7):516-8. [pmid: 7562962].
175 Marteau T, Senior V, Humphries E, et al. Psychological Impact of Genetic Testing for Familial Hypercholesterolemia Within a Previously Aware Population: A Randomized Controlled Trial. Am J Med Genet. 2004;128A:285-93. [pmid: 15216550].
176 Qureshi N, Modell B, Modell M. Timeline: Raising the profile of genetics in primary care. [Review] [55 refs]. Nature Reviews Genetics. 2004;5(10):783-90.
177 Waern U, Hedstrand H, Aberg H. What middle-aged men know of their parents’ cause of death and age at death. A comparison between history and death certificate. Scand J Soc Med. 1976;4(3):123-9. [pmid: 996471].
178 Williams RR, Hunt SC, Barlow GK, et al. Health family trees: a tool for finding and helping young family members of coronary and cancer prone pedigrees in Texas and Utah. Am J Public Health. 1988;78(10):1283-6. [pmid: 3421383].
179 Qureshi N, Bethea J, Modell B, et al. Collecting genetic information in primary care: evaluating a new family history tool. Fam Pract. 2005;22(6):663-9. [pmid: 16055464].
180 Frezzo TM, Rubinstein WS, Dunham D, et al. The genetic family history as a risk assessment tool in internal medicine. Genet Med. 2003;5(2):84-91. [pmid: 12644777].
181 Colombet I, Dart T, Leneveut L, et al. Combining risks estimations and clinical practice guidelines in a computer decision aid: a pilot study of the EsPeR system. Stud Health Technol Inform. 2003;95:525-30. [pmid: 14664040].
182 Pharoah PD, Stratton JF, Mackay J. Screening for breast and ovarian cancer: the relevance of family history. [Review] [40 refs]. Br Med Bull. 1998;54(4):823-38. [pmid: 10367417].
183 Qureshi N. Summary of WONCA 98 workshops: family doctors talk genetics. European Journal of General Practice. 1999;5(1):33-4.
184 McDaniel SH, Campbell TL, Seaburn DB. Family-oriented primary care: a manual for medical providers. New York. Springer-Verlag. 1990.