# Executive Summary

## Background

Family history (FH) represents the integration of shared genomic and environmental risk factors.1 First degree relatives (1DRs) share half their genomic information (roughly one copy of 30–50,000 genes), and also behaviors, lifestyles, beliefs, culture, and physical environment, so their disease experience may offer a clue to shared susceptibilities. This suggests that a ‘low tech’ clinical approach–family history–might be a practical and useful way to target interventions and disease prevention efforts to those most at risk. There is empirical evidence to support the common observation that a positive FH confers an extra risk for many diseases: for example, detailed meta-analyses have convincingly demonstrated the association between having one or more 1DRs and risk of a number of common, complex disorders. However, appreciation that there is a link between FH and disease risk needs to be matched by evidence-based approaches to capturing and using such information in different clinical contexts.

This systematic review attempts to address five key issues relevant to the practical value of systematically collecting FH information in primary care practice; what are the most useful elements of FH for assessing disease risk; can we be confident that individuals report FH for common diseases sufficiently and accurately; does systematic collection and use of FH information lead to positive health outcomes, and are there associated harms; what factors promote or hinder collecting and using FH information?

The focus of this review is FH collection within the primary care context, where unselected populations present the full range of disease risks, where primary care practitioners undertake the activity, and where the goal is chronic disease risk assessment and prevention as an end in itself.

### Scope and Purpose of the Systematic Review

This systematic review addresses five research questions (Q) relating to routine use of FH information in risk assessment for complex disorders, as follows:

- Q1. What are the key elements of a family history in a primary care setting for the purposes of risk assessment for common diseases?
- Q2. What is the accuracy of the family history, and under what conditions does the accuracy vary?
- Q3. What is the direct evidence that routinely getting a family history will improve health outcomes for the patient and/or family?
- Q4. What is the direct evidence that routinely getting a family history will result in adverse outcomes for the patient and/or family?
- Q5. What are the factors that encourage or discourage obtaining and using a family history?

Research recommendations from each of these five questions were to be drawn together to answer Q6 in the conclusion.

- Q6. What are future research directions for assessing the value of family history for common diseases in the primary care setting?

## Methods

The five key research questions required interrogation across different domains of primary research literature. Therefore, standard systematic review methodology was employed, but eligibility criteria varied between questions. For all questions, these criteria were guided by discussion with the technical expert panel and partners.

Bibliographic databases searched for this review included: MEDLINE^®^, EMBASE^®^, CINAHL^®^, Cochrane Controlled Trial Register (CCTR)^®^, and PsycINFO. Years searched were 1995 to March 2, 2009 inclusive.

Eligibility criteria included English studies evaluating collection of FH for all diseases, with the exception of Q1 where we limited studies to those evaluating primary cancers (breast, colorectal, ovarian, prostate, and lung), cardiovascular diseases, mental health disorders, diabetes, asthma, and atopy. Interventions were defined as a structured/systematic collection of FH (Q1, 2, 3, and 4) or as correlates or factors facilitating or hindering the collection of FH (Q5). Populations were limited to those unselected for risk and typical for primary care settings with the exception of Q2. Study designs varied by research question; we excluded case control studies for Q1, observational studies for Q3 and Q4, and qualitative studies for all questions. The outcomes also varied with each research question and included disease incidence, metrics of accuracy, uptake of recommended preventive interventions, harms (e.g., psychological distress), and quality of FH collection.

For research Q1, the analysis was aimed at comparing the discriminatory accuracy of different definitions of ‘positive’ FH, which might be used in routine clinical practice. Recognizing that the time and resources available for FH taking in these settings may be very limited, we developed a categorization of FH definitions to reflect the ‘complexity’ of the task (category A to E). It is important to note that this initial attempt at categorization is based on a notion of ‘likely effort required’, not on any a priori notion of the information value of the pedigree itself. Our rationale is that the FH definition which balances ‘adequate’ predictive validity with least effort (lowest category) might be the most likely to be useful in routine primary care settings.

## Results

The search yielded 32,444 unique citations. During three levels of title and abstract screening, 31,190 articles were excluded. A total of 1,254 citations proceeded to full text screening. After the final eligibility screening, 137 publications were eligible for data extraction.

## Question 1. What are the Key Elements of a Family History in a Primary Care Setting for the Purposes of Risk Assessment for Common Diseases?

Sixty-one reports of 59 studies were identified which met the eligibility criteria, reported FH definitions, and presented data which could be analyzed.2–62 In addition, one paper63 did not present data which could be included in the main analysis, but was descriptively summarized because the data were directly relevant to the research question. A further 17 papers64–80 were eligible but did not define FH, and 10 papers81–90 did not report interpretable data. These are excluded from the results below. No studies addressing lung cancer or ovarian cancer were identified.

### Breast Cancer

Two longitudinal,3,4 and two cross-sectional,5,6 studies were included. Fourdefinitions of ‘positive FH’ based on affected relatives were examined in five analyses. For the longitudinal analyses, the range of sensitivities was 0.06–0.26, and specificities 0.86–0.95. The range of positive predictive values (PPVs) was 0.01–0.05, and negative predictive values (NPVs) 0.98–0.99, for breast cancer prevalences up to 2.5 percent in the study samples. For the cross-sectional analyses, the sensitivities were 0.05 and 0.15, with corresponding specificities of 0.97 and 0.90. The PPVs were 0.01 and 0.09 and NPVs were 0.99 and 0.95, for prevalences of 0.7 and 5.4 percent, respectively.

Only a few discrete FH definitions were available for comparison, and there were too few data points to examine the area under the curve (AUC) from summary receiver operator characteristics (SROC) curves. The most sensitive FH marker for risk of future breast cancer appeared to be ‘at least one affected 1DR’. Conclusions regarding FH definitions used in a cross-sectional (prevalence screening) approach are not possible because an insufficient number of studies were available with a range of definitions, although the rationale for FH in prevalence screening where other modalities exist is unclear.

### Colorectal Cancer

One longitudinal analysis (based on two separate cohort studies),7 and two cross-sectional studies,8,9 were included. Four definitions of ‘positive FH’ were examined in multiple analyses, all focusing on 1DRs. The interpretation of the longitudinal analyses is limited because only one criterion for positive FH was used, (i.e., at least one affected 1DR). Sensitivities of 0.13 and 0.14 were obtained for the male and female cohorts with a specificity of 0.92 for both. For both cohorts, the PPVs were 0.02 and the NPVs 0.99, for underlying colorectal cancer frequency in these two cohorts of approximately 1 percent. For the cross-sectional analyses, the range of sensitivities was 0.00 to 0.20, and specificities 0.88 to 1.00. The range of PPVs was 0.00 to 0.07 and NPVs of 0.96 or higher, for overall colorectal cancer prevalences ranging from <1 to 4.5 percent. The AUC for cross-sectional studies for category C FH definitions was 0.64.(based on one study).

The results suggest that a simple definition of ‘positive FH’ (≥R) is the most sensitive for prediction, but if the underlying disease prevalence was similar to those populations studied, only 2 percent of people fulfilling this definition would actually go on to develop colorectal cancer (CRC) in the subsequent 16–20 years. The cross-sectional studies produced a range of sensitivities with similarly low PPVs for detecting current disease. The findings provide no definitive evidence of the superiority of one definition over any other for predicting future risk of colorectal cancer or assessing the likelihood of current disease.

### Prostate Cancer

Four longitudinal,10–13 and two cross-sectional,14,15 studies were included. Ten discrete definitions of ‘positive FH’ were examined. For the longitudinal analyses, the range of sensitivities was 0.00–0.21, and specificities 0.88–1.00. Omitting one study using mortality as the outcome, the range of PPVs was 0.11–0.26, and NPVs 0.92–1.00, for prostate cancer prevalences up to 8.7 percent. For the cross-sectional analyses, range of sensitivities was 0.01–0.26 and specificities 0.91–1.00. The PPVs were 0.02–0.14 and NPVs 0.96–0.98, for prostate cancer prevalences up to 8.7 percent.

The majority of definitions available for analysis were based on 1DRs and, for longitudinal studies, the overall AUC for category B FH definitions was 0.51 and for category, C was 0.93. This suggests a step up in the overall accuracy of classification of future risk of prostate cancer when FH of 1DRs generally is taken into account compared with specifically parental or sibling history. It was not possible to calculate this metric for cross-sectional studies. The utility of using FH to predict risk of future prostate cancer or detect current disease depends on which of sensitivity, specificity, and overall classification accuracy would be prioritized in routine practice.

### Coronary Heart Disease

Five longitudinal,16–20 and three cross-sectional,21–23 studies were included. Seventeen discrete definitions of ‘positive FH’ were analyzed. For the longitudinal analyses, the range of sensitivities was 0.03–0.51 and specificities 0.66–0.98. The range of PPVs was 0–0.13 and NPVs 0.66–0.98, for coronary heart disease (CHD) prevalences up to 10.4 percent. For the cross-sectional analyses, the range of sensitivities was 0.07–0.70 and specificities 0.53–0.98. The range of PPVs was 0.08–0.31, and NPVs 0.83–0.98, for CHD prevalences up to 20.7 percent.

Generally speaking, the highest sensitivities for prediction of future CHD risk were observed for the FH definition, ‘at least one affected parent’, although these also had lower specificities than other FH definitions. For category B FH definitions, the AUC was 0.57. For the assessment of possible current disease, the definition ‘at least one affected 1DR’ had a sensitivity of 70 percent, but it was derived from a single study in which the knowledge of disease status may have influenced awareness of FH. The findings are not sufficiently definitive to indicate a specific FH definition as the most efficient for screening or prediction of future CHD, but provide the foundation for considering how to approach such analyses.

### Stroke

Three longitudinal studies24–26 were included, allowing examination of three separate definitions of ‘positive FH’, all relating to parental illness. The range of sensitivities was 0.05–0.33, and specificities 0.71–0.98. The range of PPVs was 0.0.02–0.08 and NPVs 0.96–0.98, for prevalences of stroke up to 3.9 percent. There were no cross-sectional studies.

Many of the analyses were derived from one study,25 and do not provide definitive evidence for the utility of any particular FH definition for predicting the risk of stroke in the future. The AUC for these category B FH definitions was 0.43.

### Diabetes

Five longitudinal,27–31 and 12 cross-sectional,32–43 studies were included, along with the findings of a cross-sectional study63 designed to examine different FH definitions but which did not have analyzable data. Twenty different definitions of ‘positive FH’ were analyzed.

For the longitudinal analyses, the range of sensitivities was 0.02–0.47, and specificities 0.79–1.0. The range of PPVs was 0.02–0.38, and NPVs 0.86–0.99, for underlying diabetes prevalences up to 16.2 percent. For the cross-sectional analyses, the range of sensitivities was 0.02–0.83 and specificities 0.44–0.99, for prevalences up to 17.4 percent. One cross-sectional study63 reported the results of applying a three-level, FH-based, risk stratification system to representative U.S. adult survey data, where the overall diabetes prevalence was approximately 6.6 percent. Three FH definitions were applied, with sensitivities of 0.19–0.48 and specificities of 0.70–0.94. PPVs were 0.05–0.15 and NPVs were 0.95–0.98.

Overall, category C FH definitions for prediction of future disease risk (≥fected 1DR) had an AUC 0.43. The cross-sectional analyses examined a wide range of definitions, but many were assessed within the same study. Some of the highest sensitivities in the review were observed for the cross-sectional diabetes data, although the expected trade-off with specificity was also noted. The AUC figures for category B, C, and D FH definitions were similar (0.69, 0.71, and 0.64, respectively) suggesting no useful step up in discriminatory accuracy with extension of FH enquiry beyond 1DRs.. If the findings were replicated in further studies, they might suggest utility in using simple FH markers in preliminary triaging for diabetes screening.

### Asthma and Atopic Disease

Sixteen studies (17 publications) were included, four longitudinal,44–46,48 eleven cross-sectional,2,49–58 and one59 which was treated as cross-sectional, presenting a followup analysis of a random sample of another eligible study.58 Four studies45,46,48,57 were relevant to atopic disease alone, ten2,49,51–56,58,59 to asthma alone, and two44,52 presented analyses for both asthma and atopic disease. Ten separate definitions of ‘positive FH’ were analyzed.

For the longitudinal analyses of atopy, the range of sensitivities was 0.15–0.64, and specificities 0.44–0.91. The range of PPVs was 0.25–0.46 and NPVs 0.7–0.84, for atopy prevalences up to 38.6 percent. For the cross-sectional analyses of atopy, the range of sensitivities was 0.23–0.48, and specificities 0.56–0.83. The range of PPVs was 0.28–0.52 and NPVs 0.68–0.74, for atopic disease prevalences up to 36.2 percent.

For the longitudinal asthma analyses, the range of sensitivities was 0.18–0.69 and specificities 0.43–0.91. The range of PPVs was 0.17–0.25 and NPVs 0.86–0.89, for an asthma prevalence of 14.8 percent. For the cross-sectional analyses, the range of sensitivities was 0.04–0.76 and specificities 0.46–0.99. For the childhood studies only, the range of PPVs was 0.08–0.51 and NPVs 0.82–0.92, for asthma prevalence up to 19.8 percent. For the two adult studies, the PPVs were 0.07, 0.13, and NPVs 0.96 and 0.98, respectively, for prevalences of asthma of 3.1 and 5.5 percent.

The longitudinal and cross-sectional atopy studies did not have sufficient independent data to undertake an AUC analysis. The longitudinal asthma analyses also focused on early childhood onset, and were all based on a single study. There seemed to be a clear increase in sensitivity with looser definition of FH, and a concomitant reduction in specificity, but the discriminatory accuracy was poor (AUC of 0.56). For the cross-sectional studies, category B FH definitions had AUCs of 0.73 (father had asthma) to 0.78 (mother had asthma) and category C definitions had an AUC of 0.67, suggesting that identifying disease in one parent provides maximum predictive information. For both disease outcomes (asthma and atopy), the cross-sectional studies were potentially subject to differential reporting of FH according to awareness of disease status.

### Mental Illness

One longitudinal,60 and one cross-sectional,62 study were included. Both examined outcomes to 26 years of age, and presented data on prediction of major depressive disorder (MDD); one study60 also examined the mood disorder as an outcome condition, considered a more appropriate measure in childhood and adolescence. The longitudinal study60 followed up the third generation of a family study in which the grandparents of the participants formed the inception cohort. Four definitions of ‘positive FH’ were examined.

For the longitudinal analyses of MDD, the range of sensitivities was 0.72–0.83 and specificities 0.40–0.59; for mood disorder, the range of sensitivities was 0.73–0.83 and specificities 0.42–0.63. The range of PPVs for MDD was 0.14–0.18 and NPVs 0.92–0.95; for mood disorder, the corresponding metrics were 0.24–0.31 and 0.89–0.92. The overall prevalence of MDD for this study was 11.2 percent, and of mood disorder was 18.6 percent. A relatively high proportion of participants met at least one of the definitions for positive FH (44.1–62.7 percent), reflecting the constitution of the original cohort.

The cross-sectional analyses produced sensitivities of 0.12 and 0.24 and specificities of 0.85 and 0.96, respectively. The PPVs were 0.33 and 0.45, and NPVs were 0.79 and 0.78, respectively, for a prevalence of MDD of 23.2 percent.

For prediction of MDD and mood disorders up to early adulthood, all three FH definitions produced sensitivities at the high end of the range observed in this review. They were derived from a single study and their applicability to routine primary care practice is unclear. For the cross-sectional study, only two FH definitions were examined, and no definitive conclusions can be drawn regarding the utility of either for screening for underlying MDD. It was not possible to calculate AUC for any of this data.

## Question 2. What is the Accuracy of the Family History, and Under What Conditions Does the Accuracy Vary?

A total of 37 publications evaluated the accuracy of reporting FH and were eligible for data extraction. There were 16 studies that evaluated accuracy of reporting cancer FH. These studies recruited probands with breast cancer,91–94 colorectal cancer,95–97 prostate cancer,98,99 ovarian cancer,100 mixed cancers (breast, ovarian, colorectal),101,102 Ewing’s Sarcoma,103 lymphoma,104 melanoma,105 and unspecified cancer.106 Subjects were recruited predominately from specialized settings or cancer registries, which would suggest high risk of spectrum and selection bias. Twelve studies evaluated accuracy in persons with mental health disorders that included persons with Schizophrenia,107–109 persons with dementia or depression,110–113 and mixed disorders.114–117 Nine studies evaluated other diseases that included Parkinson’s disease,118–120 diabetes, 121–124 hypertension,121,123,125–127 and other cardiovascular disease.123–125,128 One study collected family history but reported only on the accuracy of informant age of onset rather than accuracy of disease status in the relatives; as such the results were not extracted for our research question.118

The methods for FH collection varied across studies as did the questions or tools used to collect FH. Some used highly standardized instruments and others used dichotomous probing (presence or absence of disease in any relative). Methods used to verify relatives’ disease status were primarily multimodal (medical records, disease or death registry, contact with relative) and relatives for whom verification could not be obtained were excluded from analyses.

Most studies probed the accuracy of reporting the same disease as that within the proband/informant, but some studies probed a variety of disease outcomes, for example any cancer or any mental health disorder. Overall, specificity across all disease types and with varying modes of FH collection was consistently high. Sensitivities were lower and generally more variable depending on the disease outcome. Some of the mental health disorders showed the lowest sensitivities, breast cancer, and cardiovascular disease showed the highest values.

Several studies evaluated predictors of accuracy in reporting FH. Factors related to the proband/informant includes age, gender, disease status, education level, race, marital status, type of disease, setting, and insurance status. Predictive factors associated with the relatives include, degree of relation, type of 1DR, disease subgroup, age, gender, and time since diagnosis. No clear trend emerged with age, gender, or education level of the informants and their impact on accuracy. No clear pattern across diseases emerges with the exception that there was a consistent trend towards increased accuracy of reporting relating to 1DRs compared to 2DRs or 3DRs; however, the majority of studies evaluated only 1DRs. Overall, these 37 studies had a high risk of spectrum bias (populations highly selected and not reflective of primary care), verification bias (different methods used inconsistently), and masking bias which may cause an overestimation of accuracy.

## Question 3. What is the Direct Evidence That Routinely Getting a Family History Will Improve Health Outcomes for the Patient and/or Family?

We selected studies that identified the impact on health related outcomes of systematic collection of FH in a typical, non-selected primary care/general population. Only two studies were identified after full text review.129,130 Both studies were uncontrolled before-after designs and focused on breast cancer risk assessment, including FH collection, as the target intervention. In both studies, there was limited improvement in the clinically relevant process measure of mammography screening. In one study129 mammography screening improved from 76 to 93 percent, however, the matched sample was small (n=29) and the change in screening did not reach statistical significance (p=0.057). There was no differentiation of the improvement in breast screening habits between the different risk strata. In the second study there was also limited improvement in adherence to mammography in all women (p=0.796) and for each age group (40–49; >=50 years old). Further, in women with high breast cancer risk (relative risk >=1.7) the adherence fell from 81 percent (17/21) to 71 percent (15/21), although this did not reach statistical significance (p<0.317). Both studies also demonstrated improvements in adherence to other process measures: breast self exam (BSE) and clinical breast exam (CBE). Both studies were at risk of selection bias sufficient to affect the interpretation of the results.

## Question 4. What is the Direct Evidence That Routinely Getting a Family History Will Result in Adverse Outcomes for the Patient and/or Family?

Three studies met all eligibility criteria.131–133 These comprised a randomized controlled trial 133 and two uncontrolled before after studies.131,132 Each of studies recruited patients from single British primary care office network with the number of respondents recruited varying and response rates of 19, 29, and 64 percent respectively. The proportion of recruited patients completing survey items at all time points was 91, 89, and 76 percent respectively. These studies suggest that structured FH collection and feedback of familial risk information had no deleterious psychological effects on patients at 6 to 12 weeks after FH intervention. One study131 further identified the relationship between breast cancer familial risk status and psychological impact. As well as having no deleterious psychological effect in any of the risk groups, for women who were at or just above average risk, the FH risk assessment may have led to appropriate reductions in perceived risk.

## Question 5. What are the Factors That Encourage or Discourage Obtaining and Using a Family History?

Six studies were identified, four of which were undertaken in primary care offices.134–137 The other two studies’ populations were derived from patients being screened in the general population.138,139 Four studies were cross-sectional.135,136,138,139 The remaining two studies were a direct observational study137 and a prospective cohort study with a baseline cross-sectional survey.134 Factors associated with FH collection or discussion were the primary outcomes of interest of three studies.136,137,139 These data were retrieved in the other three studies from sub analyses presented in these publications.134,135,138 Two studies only recruited female patients.136,138 The identified outcomes of interest were: FH documented in medical records;134,136 FH discussed by doctor, either confirmed by direct observation137 or patient survey;135,138 and self reported FH.136,139 Women appeared to be better informants than men were and younger physicians were more enthusiastic about discussing FH. There were disparities in FH collection and reporting in underserved groups, specifically non-white ethic groups,136,139 those with lower educational status,139 and those on state health insurance.137

The evidence base for addressing Q5 is heterogeneous and limited to six studies exploring the association between various factors and FH reporting, documentation and discussion. In most studies the nature of the FH discussed or reported was not clearly identified, often just reported as dichotomous variables. Representativeness of these surveys is also limited by response bias and recall bias. Collectively, these issues limit the generalizability of the study findings, hence caution should be observed in applying this information to clinical situations in primary care.

### Discussion and Conclusions

This review was designed to inform a broad range of questions which ultimately address the clinical value of using FH in chronic disease risk assessment and prevention. The findings from studies reviewed in Q1, Q2, and Q5 should inform the nature and content of future FH tools, which should be developed according to the context in which the tools are being applied. A tool used for an initial general FH screening enquiry, such as during a new patient intake visit or routine physical examination, would generally be less focused than one developed for a specific purpose, such as identifying possible familial risk in a woman concerned because of a breast cancer diagnosis in a sibling. The starting point should be clarifying the minimal FH dataset necessary for each purpose, taking account of the evidence for accuracy, recall, and relevance of each piece of information.

1. Very few studies were designed to address Q1 directly, and the metrics reported usually related to strength of association between FH and disease incidence or prevalence rather than discriminatory ability when applied to individual patients. Our analyses were based largely on a re-examination of data generated for other research purposes. In most cases, positive FH, however defined, had no more than modest ability to correctly classify future risk of complex disorders in individuals. This is logical, because, by definition, they are not high penetrance single gene disorders. The required level of predictive accuracy depends on the purpose of the FH assessment, and the benefits, risks, and costs of decisions made based on the risk assessment. In principle, the definition of ‘positive FH’ which combines adequate predictive accuracy with the least effort to obtain it would be most suited to busy primary care settings.
  Recommendations for direction of future research:
  - Further clarification of the purpose of FH taking in primary care settings is required, so that future assessments of the utility of FH are based on an appreciation of the level of predictive accuracy that is required for the specific situation.
  - The evidence base requires studies designed explicitly for the purpose of examining the predictive ability of different ‘minimum’ FH definitions. This requires adequately powered, longitudinally designed studies in which detailed, extensive, clearly defined and documented FH components comprise the ‘exposures’, in which participants are followed up for a period which is clinically meaningful, in which adequate measures are taken to control bias, and in which the primary metrics relate to individual risk prediction.
  - FH items should be formally examined alongside other recommended or readily accessible risk factors, in order to identify the extent to which they provide (or need to provide) useful independent and/or incremental discriminatory ability.
2. The accuracy of self reported FH has implications for the correct risk assessment and management of patients. Accurate reporting of the absence of disease (specificity) appears to be more common than accurate reporting of presence of disease (sensitivity) across different disease areas. Estimates of sensitivity show greater variation and the magnitude varies with different diseases. Although, there is limited evidence, accuracy of recall and reporting may be influenced by both patient and informant (relative) factors, and by the method used to collect FH. Accuracy of FH reporting may also be dependent on the method of collection, which is related to the disease area however, further evaluation is needed.
  Recommendations for direction of future research:
  - Future studies in accuracy should be undertaken in populations reflective of the primary care setting and representative of the spectrum of disease risk.
  - Future studies should endeavor to better characterize the attributes of the informant/proband and especially the relatives; the potential of these factors to influence the accuracy of reporting should be consistently evaluated. Future evaluation should be undertaken in the areas of asthma and atopy, affective mental health disorders, cardiovascular diseases, and diabetes.
3. Within primary care populations, there is very limited evidence to support or refute the effect on risk-reducing behavior changes of taking a FH and using it to personalize risk of developing respective conditions.
  Recommendations for future research:
  - Well designed trials are required that compare the impact of FH-based, personalized risk advice with standard of care on risk reducing behaviors in populations at different risk levels (including population risk). The outcomes of interest need to be clinically relevant, either leading to improved mortality or morbidity or surrogate measures with strong evidence of links to improved health outcomes. Concurrent qualitative studies should also be considered.
  - Proposed trials should be based on evidence from systematic reviews to ensure that prescribed risk-reducing behaviors are evidence-based.
4. In primary care populations, there is very limited information to evaluate direct harm incurred from the routine practice of taking FH and using it to personalize risk information.
  Recommendations for future research:
  - Trials of FH taking as an intervention should include capture of data to examine the full range of potential impacts on individuals of FH collection and implementation strategies based on familial risk identification, both negative and positive. Concurrent qualitative studies should also be considered. Baseline data on psychological status should be captured so that this can formally be adapted for use in outcome analyses. To enable appropriate evaluation of psychological harm, context-specific measures need to be developed and validated.
5. In order to assess the content validity of systematic FH tools we need to know not only the factors that affect the recall of FH (Q2) but also those factors that affect the collection and use of FH. Thus far, there is limited information on collection and discussion of FH in primary care, with no factors identified that are associated with the use of the FH. There is some suggestion that populations from underserved communities are less likely to report and have the opportunity to discuss FH, but the level of evidence is weak.
  Recommendations for future research:
  - Further research is required to clarify the most important patient and practitioner factors that may affect the collection and use of FH. This likely requires the development of theoretical frameworks to guide appropriate design, and to ensure that methodologies adequately address the many potential biases and interactions between factors which may be encountered. The most important studies are those that address factors directly relevant to primary care practice, including highlighting patient factors which promote inequity in the application of effective interventions
  - Where inequities are identified, interventions should be designed to ameliorate these factors in future trials and service provision. Such research could include analyses of national population and practitioner survey databases.
  - While research should focus on clinically relevant outcomes, it should also include process evaluations to identify factors that affect the successful implementation of the FH interventions.