# Discussion

## Overview

This review was designed to inform a broad range of questions (Q) which ultimately address the clinical value of using family history (FH) in chronic disease risk assessment and prevention in primary care.

The evidence derived from questions (Q) 1, 2, and 5 was designed to inform primary care providers of the most efficient elements of FH information, and approaches to collection, which might be best suited to routine application, given the constraints that are faced such as limited time availability. This draws together the most informative components of an individual’s FH for future or current disease risk, the factors, which influence accuracy of reporting, and the factors, which stand in the way of, or promote, the actual collection of FH data. In addition, if primary care providers are to be persuaded that systematically collecting and interpreting FH is a beneficial activity, they need to be provided with the most robust evidence of the benefits of this intervention in improving patients’ health outcomes, and any significant adverse effects. The evidence for these issues was derived from questions 3 and 4.

## Q1. What are the Key Elements of a Family History in a Primary Care Setting for the Purposes of Risk Assessment for Common Diseases?

As discussed in Chapter 1, for FH to be useful in chronic disease risk assessment, it is not enough for patients to report, and professionals elicit, FH information accurately: it is necessary to clarify which elements of FH are most useful for disease prediction.150 In specialist genetics settings, the gold standard, comprehensive, three generation pedigree forms the foundation for identifying specific potential disease inheritance patterns, such as autosomal recessive or X-linked dominant.171,172 However, in a primary care context, the goal is usually to identify an individual’s overall level of familial risk, without necessarily seeking out specific patterns, though this is not precluded. Since, by definition, complex disorders are not likely to display an easily discernable, high penetrance pattern of inheritance, it is reasonable to take a simpler approach in which FH elements (e.g., type of relative, closeness of relationship, gender, age of onset, etc.) are combined and their predictive validity examined empirically. In principle, the FH definition which combines useful predictive power with least effort to obtain is likely to be the one best suited for routine application. Some insight into the ‘information value’ of different FH definitions might be useful in developing evidence-based, primary care-oriented FH tools,151 which could then be evaluated against appropriate control interventions for the effect of their use on health outcomes.

A large number of studies were identified that provided data relevant to this question, although they were mostly not designed for the analyses performed here. Only a very few reports were designed to examine different definitions of ‘positive FH’, and almost all assessed FH as a possible risk factor for disease in classical epidemiological approaches. Many of the cross-sectional studies were potentially subject to information bias, in relation to both exposures and outcomes: it is possible that some participants knew their FH more accurately because they were affected by the condition in question, and vice versa. In almost all studies, the strength of association between FH and disease frequency was assessed at a population level, using relative risks, odds ratios, and related metrics. However, assessing the utility of FH for risk assessment in individual patients requires examination of discriminatory accuracy metrics: sensitivity, specificity, and predictive values. The question is not so much ‘how many times more likely” are people with a given FH to develop a disorder compared to those who do not have the FH. Rather, the question is more of the nature, ‘What is the chance that, given this FH, this person will go on to develop this disease in the time period of interest?” Even for the most common complex disorders, most people ‘at risk’ do not actually go on to develop the disease, therefore even large relative risks may actually be associated with very small absolute risks over a 5 or 10 year period.

Even though most studies included did not report predictive metrics, or were not even designed to address Q1, it was still possible to extract sufficient data to begin to explore the issue of interest. We examined FH definitions in longitudinal and cross-sectional studies, appreciating that they provided different insights: the former are designed to address prediction of future disease, and the latter reflect screening for current disease. Although some analyses covered a wide range of FH definitions, we observed that most studies defined FH largely in terms of first degree relatives (1DRs), and only a few drew in information on a broader set of relatives. Very few reports provided a rationale for the specific FH definition, and it was not possible to assess the value of criteria such as age of onset or lineage in any meaningful way.

A pragmatic approach was used in approaching individual FH definitions. For example, rather than separating out mutually exclusive FH categories (e.g., ‘affected brother only’ versus ‘affected brother and sister’) for analysis, we combined categories and compared presence of that FH characteristic versus absence of that FH characteristic (e.g., ‘affected brother, irrespective of status of other relatives’ versus ‘no affected brother, irrespective of status of other relatives’). This permitted the assessment of that single FH characteristic (‘affected brother’ or ‘unaffected brother’) as if it were the only question that a health professional asked the patient, thus allowing some sense of its predictive ability as a simple screening or triage question in and of itself.

Overall, the discriminatory accuracy was generally modest, for most FH definitions used in isolation. This is not surprising – as noted previously, complex disorders do not have a strong or highly penetrant genetic component, and therefore it would be illogical to expect a very high predictive value for FH, however defined. Also not surprisingly, the most sensitive FH definitions were usually those, which were very loose, (e.g., a minimum of one affected relative, whether or not further specified). From a theoretical perspective, it would be expected that a simple, loose definition such as this would have highest chance of picking up people genuinely at high risk, but would also identify many false positives. The more elements required to define ‘positive’ FH, the less sensitive and more specific the definition, again to be expected.

Another factor, which needs to be considered, is whether the way in which FH was captured in these studies was reflective of routine clinical practice. For some studies, for example, the multigenerational cohort studies, it is clear that FH ascertainment was in no way typical of primary care practice. However, many of the definitions were simple and probably reflect the types of answers that would be received even if elicited verbally as part of an office consultation. The factors influencing accuracy of reporting were examined as part of Q2.

As part of this review, we developed a notional categorization system (Table 2) to reflect the effort required to obtain the minimum information implied by any given FH definition. We wished to take account of the time constraints under which many primary care practitioners work, and the possible limitations of immediate knowledge, which patients might bring to a consultation. The use of electronic medical records (EMR) might permit the easy assembly of more extensive FH and render the distinctions in the table irrelevant. Also, decision-support systems based on EMRs would facilitate the implementation of FH scoring systems, which represent the next ‘step up’ in FH assessment, taking into account information on factors such as family size, time at risk, etc.173 In contrast, a practitioner who may only have time to use a few ‘screening questions’ might be well served by knowing the absolute minimum level of information that needs to be elicited for a given level of predictive accuracy. While the category A-E framework is not intended to be definitive, we were able to provide some evidence that this type of approach might be useful. For example, for prevalence studies of diabetes, the AUC value for category D showed no improvement in discriminatory accuracy over categories B and C. If these observations are valid, it would indicate that simple, targeted questions about first degree relatives would be as informative as more extensive enquiry for identifying individuals at risk of undiagnosed diabetes. While these analyses can only be regarded as preliminary, they suggest an approach for future research.

Having gained some insight into the performance of specific FH definitions in predictive chronic diseases, the appropriate question is to ask next, is how they perform when considered with information on other risk factors. Depending on the disease in question, a clinician is unlikely to disregard other risk factors and base a risk assessment on FH alone. However, if a positive FH significantly improved the predictive ability of other established factors, then it might make the difference in the choice of preventive interventions, and/or in promoting risk reducing health behaviors. It was beyond the scope of this review to model the incremental predictive value of particular FH definitions combined with other risk factor variables, but this would be a logical extension of this enquiry.

It is impossible to draw an overarching conclusion from the analyses conducted for Q1, and it was not possible to assess the performance of FHs across a range of disorders. The tables detailing predictive value alongside disease prevalence were constructed to permit comparison with different clinical contexts, and to give a sense of the highest likely achievable predictive utility, within the constraints of the data. In considering these data, it is necessary to clarify the underlying prevalence of the condition in the population of interest, whether the purpose is stratification of future disease risk (and the time frame) or triaging for screening for current disease, and the way in which FH information may or may not be combined with other risk factor information for a holistic assessment of an individual patient.

## Q2. What is the Accuracy of the Family History, and Under What Conditions Does the Accuracy Vary?

In order for FH to be of value in clinical decision making, patients must possess, and primary care practitioners be able to ascertain, accurate family health information. Assessing accuracy requires a clear idea of an appropriate gold standard—what patients ‘should’ know, and what clinicians ‘should’ be able to obtain. In simple terms, an ‘accurate’ FH could be considered to be one which is sensitive (disease in relatives is correctly identified) and specific (lack of disease in relatives is correctly identified).

In order to fully explore the question of accuracy of reporting we did not restrict the population to those within a primary care setting as we correctly anticipated that there would be few accuracy studies within this population. In this regard, the majority of studies evaluated subjects with the disease or first degree relatives (1DRs) who are by definition at high risk. Overall, the applicability of these findings from specialized clinical settings to primary care settings may be limited; the high risk of spectrum bias would tend to cause overestimation in accuracy. Although, the attributes of the probands (or informants) were described, those of the relatives (for example, gender or even the relation to the proband) were not, particularly in studies within the mental health area.

Overall, the few rigorous studies, which fully evaluated accuracy consistently, suggested that informants are more accurate in identifying which relatives are free of the disease (specificity) than in identifying relatives who have been affected by cancer (sensitivity). This trend was generally consistent across all disease groups, except heart disease; there was some variation in the rates for sensitivity. For example, in the mental health area, rates of sensitivity were consistently very low (>40) but in cancer FH they were higher (~ 80 percent). Similarly, in those studies that reported sensitivity for both cases and controls, there is variation between the different disease areas; for example, sensitivities in relatives of controls probed for Parkinson’s disease were much lower than those observed in assessments of controls in breast cancer studies

Our findings also suggest that FH reporting may be more accurate for 1DRs than second degree or beyond, although few studies examined accuracy in the latter. Similarly, attributes of the informants and relatives have not been consistently evaluated; in those limited studies that did examine this factor, there was no clear pattern in the attributes of the informant or those of the relative that influence accuracy results. The methods used to collect FH and the disease category is likely to account for this inconsistency. We also have little insight into which informant characteristics are associated with more accurate reporting; future evaluations could consider formally examining factors such as sex, age, and cultural background. It is possible that informants affected by cancer may seek out more complete information on their FH after their initial diagnosis, but we were unable to confirm this within this literature.

The accuracy of reporting by probands, members of the population or relatives cannot be completely separated from the performance of tools to gather such data. We observed great variation in methods used to collect FH that ranged from simple dichotomous questions, to more complex standardized tools that had established psychometric properties. In the area of mental health, FH is an important component in establishing the presence of disease, and as such was included in both the index test and the reference standard; that is the FH of the relative (not just medical history) formed part of the case definition of what was also collected in order to establish the presence of the disorder (for example in bipolar disorders). It was challenging to disentangle medical history and FH in some of the studies within mental health; similarly, in this area FH included a broader conceptualization which included relatives such as “spouses”. Future evaluation within mental health studies would be strengthened by clarifying these differences.

Most studies evaluating accuracy used a multimodal approach to establishing the presence of disease within the relatives. In part, this was necessitated by the status of the relatives; for example, clinical examination could only be undertaken in relatives that are alive. As such, there will always be a high risk of bias for differential verification irrespective of the different disease categories evaluated. It is impossible to comment on which gold standard is ‘best’ for judging accuracy, but we recognize that multiple strategies are necessary to capture the status of all relatives.

Future efforts to improve accuracy of reporting would be improved by explicit consideration of whether sensitivity or specificity is the primary goal, which is dependent on the clinical context and purpose of a FH oriented strategy. For example, maximizing sensitivity prioritizes the goal of missing as few ‘at risk’ family histories as possible, and is consistent with a policy in which the potential benefits from finding potential cases carry more weight than the potential costs and harms of investigating individuals or families with false positive histories. In contrast, maximizing specificity prioritizes avoiding the potential costs and harms of false positives, and is consistent with a policy that directs limited resources towards only identifying individuals or families with the greatest likelihood of being at significant disease risk, at the cost of missing some true positives.

In general, we might expect that the accuracy of FH reporting will improve in future, as current initiatives lead to more awareness on the part of the general public. It is not clear whether this will be countered by the effect that increased population mobility has on people’s abilities to keep up to date with the health of more distant family members.

## Q3. What is the Direct Evidence That Routinely Getting a Family History Will Improve Health Outcomes for the Patient and/or Family? AND Q4. What is the Direct Evidence That Routinely Getting a Family History Will Result in Adverse Outcomes for the Patient and/or Family?

These two research questions were identified as being complementary, and were therefore approached together in this discussion.

While the literature contains many observational studies examining the association between awareness of familial disease risk and patient risk behavior, psychological distress and uptake of services (see Webtable 30 for list of observational studies) they do not identify the temporal sequence from risk awareness to change in relevant outcomes. Thus, they do not provide clear evidence that family history collection and/or risk identification as a deliberate clinical activity in itself leads to changes in health outcomes. As demonstrated in the review, there is very limited information available from such robust intervention studies.

The focus of this review was to inform primary care practice, and we identified few studies conducted in a general population or non-specialist context. This is not surprising, considering that when familial risk assessment is offered to general populations (not specially selected for risk), the response rate is usually low. In the reviewed studies, the FH collection interventions were predominately integrated in multifactorial risk assessment tools particularly in the two studies examining improvements in health outcomes (Q3). Although these studies were not in a primary care office setting, they did approach the general population through respondent-initiated enquiry. These models suggest that the modality of risk assessment may affect the use of this service. Anonymous telephone-based risk assessment services may attract patients already aware of their strong family histories (and/or other risk factors) due to concerns about insurance discrimination. This may be particularly the situation if the assessment is associated with similarly anonymous telephone based genetic counseling. However, in patients unaware of the implications of their FH, in-office assessment followed by their personal physician’s recommendation may be the preferred option.

Irrespective of the mode and type of FH assessment, the impact on risk-reducing behavior remains unclear. We identified evidence that suggests that incorporating FH collection into multifactorial risk assessment increased screening rates for breast cancer risk, but direct evidence for other conditions is lacking. Incorporating FH collection into a multifactorial risk assessment tool leads to difficulties in disentangling the effect of the FH intervention from other factors.

When considering the adverse effects of FH collection and risk assessment (Q4), only three small studies were identified. They suggest that FH collection and risk assessment increases general anxiety in the short term, with scores returning to pre-intervention levels by 6 to 12 weeks. While the short term impact of intervention is increased anxiety, the process of reviewing the FH may also reassure the clinic attendees. On the other hand, if individuals are aware that they are at low familial risk, confirmation of status on familial risk assessment would be expected to make no difference to the score. To some extent, these findings mirror those of genetic testing for adult onset disorders, in which the consistent finding is that genetic test results provoke short-term increases in anxiety which return to baseline levels within 1–2 months.174,175

However, to fully assess the psychological effect of FH collection and use as an approach to chronic disease risk prediction, validated context-specific tools need to be developed. Further, other than psychological distress, studies of other adverse outcomes were not identified (e.g., reduction in screening behavior).130

Finally, it is important to note that, even if FH collection and risk assessment had a positive net effect on risk reducing behavior, this does not provide evidence that the prescribed risk-reducing behavior leads to improved health outcomes.

## Q5. What are the Factors That Encourage or Discourage Obtaining and Using a Family History?

Although ‘taking a FH’ is a core activity in primary care,176 little is known about the factors that encourage or inhibit it. We identified only a few studies that addressed this question and they were very heterogeneous and did not provide a clear understanding of the factors that improve the appropriate collection and use of FH information in non-specialist settings, whether for general application in complex disease risk assessment or screening patients with more evident familial disease who require more focused FH collection. In many cases FH collection and use is presented as a dichotomized variable, limiting the interpretation of the data.

Despite the difficulty of synthesizing these studies, some observations are possible. To do so, it is necessary to consider together studies which examined the likelihood that FH was discussed with those which examined whether FH was recorded in patient records as a proxy for the same underlying activity, (i.e., that FH was collected, recorded, and acted upon). On this basis, there is tentative evidence to support the importance of: 1) patient factors such as gender, age, education, their ethnic group, the nature of their health insurance, 2) provider factors such as younger or older practitioners, whether or not they were residency-trained, 3) the condition of interest (e.g., the FH of some cancers appears more likely to be reviewed than other conditions), and 4) the context, including whether the consultation focuses on a specific disease or not, physical examinations, whether or it is a new patient consultation, whether or not the patient brings specific disease concerns.

There is insufficient evidence on whether organizational factors such as electronic health records, make a meaningful difference to FH capture or recording. In a previous review,145 we noted that the use of FH tools was associated with more accurate and complete recording of FH information than non-systematic approaches, but it is not clear whether providing such tools in itself promotes their routine use.

## Limitations

The studies reviewed in this report were limited to those published in English; however, the impact of any language bias is offset by the optimal applicability to English speaking countries for which this report was prepared. Given the scope of the research questions, we limited our search from 1995 to March 2009. We acknowledge that the 1995 publication date cutoff may have excluded some studies.177,178 Similarly, due to restraints of time and resources, grey literature was explored in a limited manner.

In considering the elements of FH which provide most value in predicting risk of disease (Q1), we re-analyzed data for a large number of studies, most of which were not primarily designed to address the goals of this review. We took at face value the definitions of FH as they were described in the source reports, and did not contact authors for confirmation. Neither did we attempt to assess the likely accuracy of FH reporting, nor take into account the method by which it was collected (although this was noted as a descriptive item). We grouped together data from studies that were very heterogeneous, in terms of study population and definitions of disease outcome. While almost all studies indicated that FH information was captured by structured interview or self-completion questionnaire, we cannot consider that these methods necessarily replicate the quality of information that might be obtained by a primary care practitioner in a clinical setting. Finally, the AUC calculations were restricted by the number of data points available. The findings presented should therefore be considered to give an indication only of the possible predictive ability of different FH items, rather than to be a definitive analysis.

In the context of accuracy (Q2), we did not restrict studies according to the manner in which FH was collected and considerable variation in the methods used was observed. Almost universally, studies included the collection of FH based on self-reporting (from either the proband, informant, or relative) and are therefore dependent on the individual respondents’ knowledge of their history. This represents a limitation on FH taking in practice rather than a limitation specifically of this systematic review. Additionally, eligible studies evaluating the accuracy of FH reporting did not use the same method to ascertain FH or verify status within all relatives. As such, interpretation of the metrics of accuracy was limited to the methods of FH ascertainment and verification used in these studies. Finally, when evaluating and comparing quality of studies, we assumed the index and reference tests were similar.

In examining the effects of FH taking on behavior (Q3) and adverse effects (Q4), the review was limited to populations and setting applicable to primary care. We acknowledge that systematic FH collation and interpretation in specialist setting may provide evidence relevant to primary care but the scope and pragmatic considerations limited the focus of the review. The emphasis on very specific clinical behavioral outcomes also does not allow for exploration of other effects on the part of patients, such as seeking out more extensive information from family members as a result of having been asked “the first” set of questions on FH. Further exploration of the ethico-legal and social aspects would have added a valuable perspective to the review, but there was limited information in the quantitative literature; it was beyond the scope of this report to examine the extensive and diverse qualitative literature that may have explored these aspects of FH.

In consultation with our TEP and partners, we considered the issue of how different FH tools might relate to the review questions; however, we determined that incorporating a comparison of tools, in addition to the original questions, was not feasible, and altered the already broad focus of the review. FH tools for cancer have been examined in a previous AHRQ systematic review,145 this review identified several generic FH tools.179–181 Another systematic review has also examined cancer and generic tools applicable to primary care settings.146

## Conclusion

Firstly, we explore the implications of the individual questions.

1. The main analysis drew on data from studies designed to address other primary questions, but yielded some useful quantitative information, which indicates the likely upper limit on predictive utility of different FH definitions for the diseases of interest, where FH is used in isolation as a risk factor. The analysis was constrained by the definitions of FH used in the primary studies, but we developed a notional approach to categorizing FH definitions to assist interpretation of their workload impact in routine clinical settings. In and of themselves, very few of the specific FH items or combinations examined had more than modest ability to predict future disease risk in individuals. In general, the least constrained definitions (e.g., at least one affected 1DR, with no other information required) were generally associated with higher sensitivities and lower specificities. This conclusion is not surprising, since a very high predictive ability based on FH alone would imply a disorder with a strong genetic element and high penetrance. For complex disorders, even modest independent discriminatory ability might provide clinically useful predictive information in combination with other risk indicators readily available to the primary care practitioner.
  It is worth noting the importance of considering the complexity of the FH definition itself and its relationship with the type of risk information it conveys. The most complex definitions, particularly those which incorporate lineage (Category E, Table 2, Chapter 2), appeared to be designed to identify Mendelian-type patterns of inheritance.182 As such, they would therefore be expected to identify rare population subgroups with a “genetic version” of a complex disorder. Such an approach is, by definition, likely to be highly specific and but rather insensitive. In contrast, a positive FH based on a very simple definition might provide a marker which picks out a higher than average ‘familial loading’ for a disorder, but has no need to consider detailed pedigree information. This approach would be characterized by higher sensitivity but lower specificity. The purpose of the FH assessment in primary care (to pick out very high risk subgroups for further genetic assessment or to work out more general familial disease loading) merits further discussion.
  Recommendations for direction of future research:
  - Further clarification of the purpose of FH taking in primary care settings is required, so that future assessments of the utility of FH are based on an explicit distinction between, for example, disease risk assessment as part of routine preventive care (e.g., the routine physical examination) in which other risk information is taken into account, triage for screening (e.g., selecting people for formal tests of glucose tolerance), or applying genetic referral/testing guidelines in patients who appear to have a prominent familial disease history, in whom genetic disease is suspected.
  - The evidence base requires studies designed explicitly for the purpose of examining the predictive ability of combinations of individual FH items. This requires adequately powered, longitudinally designed studies in which detailed, extensive, clearly defined and documented FH components comprise the ‘exposures’, in which participants are followed up for a period which is clinically meaningful, in which adequate measures are taken to control bias, and in which the primary metrics relate to individual risk prediction.
  - FH items should be formally examined alongside other recommended or readily accessible risk factors, in order to identify the extent to which they provide useful independent and/or incremental discriminatory ability.
2. The accuracy of self reported FH has implications for the correct risk assessment and management of patients. Accuracy of FH reporting appears to be dependent on the method of collection, which is related to the disease area. Accurate reporting of the absence of disease (specificity) appears to be greater than accurate reporting of presence of disease (sensitivity) across different disease areas. Estimates of sensitivity show greater variation and the magnitude varies with different diseases. Although, there is limited evidence, accuracy of recall and reporting may be influenced by both patient and informant (relative) factors, and by the method used to collect FH.
  Recommendations for direction of future research:
  - Future studies in accuracy should be undertaken in populations reflective of the primary care setting and representative of the spectrum of disease risk. Future studies should endeavor to better characterize the attributes of the informant/proband and especially the relatives; the potential of these factors to influence the accuracy of reporting should be consistently evaluated. Future evaluation should be undertaken in the areas of asthma and atopy, affective mental health disorders, cardiovascular diseases, and diabetes.
3. Within primary care populations, there is very limited evidence to support or refute the effect on risk-reducing behavior changes (e.g., lifestyle changes or uptake of recommended clinical interventions) of taking a FH and using it to personalize risk of developing respective conditions.
  Recommendations for future research:
  - Well-designed trials are required that compare FH-based, personalized risk advice with standard of care on risk reducing behaviors in populations at different risk levels (including population risk). The outcomes of interest need to be clinically relevant, either leading to improved mortality or morbidity or surrogate measures with strong evidence of links to improved health outcomes. Concurrent qualitative studies should also be considered.
  - Proposed trials should be based on evidence from systematic reviews to ensure that prescribed risk-reducing behaviors are evidence-based.
4. In primary care populations, there is very limited information to evaluate direct harm incurred from the routine practice of taking FH and using it to personalize risk information.
  Recommendations for future research:
  - Trials of FH taking as an intervention should include capture of data to examine the full range of potential impacts on individuals of FH collection and implementation strategies based on familial risk identification, both negative and positive. Concurrent qualitative studies should also be considered. Baseline data on psychological status should be captured so that this can formally be adjusted for use in outcome analyses. To enable appropriate evaluation of psychological harm, context-specific measures need to be developed and validated.
5. In order to assess the content validity of systematic FH tools we need to know not only the factors that affect the recall of FH (Q2) but also those factors that affect the collection and use of FH. Thus far, in this population, there is limited information on collection and discussion of FH by the population and practitioners, with no factors identified that are associated with the use of the FH. There is some suggestion that populations from underserved communities are less likely to report and have the opportunity to discuss FH, but the level of evidence is weak.
  Recommendations for future research:
  - Further research is required to clarify the most important patient and practitioner factors that may affect the collection and use of FH. This likely requires the development of theoretical frameworks to guide appropriate design, and to ensure that methodologies adequately address the many potential biases and interactions between factors, which may be encountered. The most important studies are those which address factors directly relevant to primary care practice, including highlighting patient factors which promote inequity in the application of effective interventions
  - Where inequities are identified, interventions should be designed to ameliorate these factors in future trials and service provision. Such research could include analyses of national population and practitioner survey databases.
  - While research should focus on clinically relevant outcomes, it should also include process evaluations to identify factors, which affect the successful implementation of the FH interventions.

The findings of this systematic review pose as many questions as they answer, but they do not undermine the general view that FH taking is a worthwhile activity in primary care settings. The evidence base for FH-based assessment and intervention is not well-developed, but absence of evidence is not absence of effect. The few studies that have examined potential harms of FH taking suggest that such concerns may be unfounded, and should not hinder the development of rigorous evaluations of FH taking and FH-based risk interventions. There is consistent evidence from a previous report145 that FH tools (albeit for cancer) promote higher quality information capture than non-systematic approaches. The findings from this systematic review begin to suggest how to choose FH items to populate tools and emphasize the importance of considering purpose (to what use will FH information be put?) and context (time available, and nature of clinical encounter).

Finally, although this systematic review identified the paucity of relevant evidence for many important issues, the findings do not negate the “extraordinary potential of the FH” in primary care practice.183 The systematic and often graphical collation of this information (e.g., as genograms) in family-oriented clinical practice may be used for purposes which go beyond specific disease risk assessment, for example to assess the impact of “family health” (broadly defined) on an individual’s well-being.184 Family practice, in particular, is characterized by the continuity of the relationship between, patients, families, and practitioners. Thus, in the real world, FH may be pieced together over time and decision-making may be incremental as more information emerges. A deeper appreciation of the context in which FH is captured, interpreted, and acted upon is important as further FH based interventions are developed and evaluated.