# Results

Figure 2 details the flow of studies and the final subset for reviewing. The search yielded 32,444 unique citations. During three levels of title and abstract screening, 31,190 articles were excluded. A total of 1,254 citations proceeded to full text screening. After the final eligibility screening, 137 publications were eligible for data extraction.

Figure 2 Flow of studies through review

## Question 1. What are the Key Elements of a Family History in a Primary Care Setting for the Purposes of Risk Assessment for Common Diseases?

### Introduction

Sixty-one reports of 59 studies were identified that met the eligibility criteria, reported family history (FH) definitions, and presented data which could be analyzed.2–62 In addition, one paper63 did not present data which could be included in the main analysis, but was descriptively summarized because the data were directly relevant to the research question. A further 17 papers64–80 were eligible but did not define FH, and 10 papers81–90 did not report interpretable data. These are excluded from the results below.

### Note on Interpretation of Results

Data are presented below for both longitudinal and cross sectional analyses. The most common approach to assessing the contribution of FH to disease risk is to measure strength of association (i.e., how many times higher the incidence or prevalence of the disorder is in people with the FH than people without). The metrics used can include relative risk (RR), odds ratio (OR), hazard ratio (HR) and others. These do not provide an estimate of individual probability of disease. For this systematic review, FH is approached as if it was a ‘test’, and predictive accuracy metrics are used to judge performance. In this situation, each FH definition is considered to be a different ‘calibration point’ (the cutoff for ‘positive’ or ‘negative’ result) for the ‘FH test’. The longitudinal analyses provide an estimate of how well different FH definitions predict the occurrence of future disease in individual study participants. The cross sectional analyses provide an estimate of how well different FH definitions discriminate between individuals who currently have and do not have the disease of interest. Longitudinal studies examine prediction of future cases, while cross sectional studies examine current disease. Four metrics are used to assess the performance of different FH definitions:

- Sensitivity – provides an estimate of the proportion of future or current cases which are correctly identified by the particular ‘positive’ FH definition
- Specificity – provides an estimate of the proportion of individuals destined to be disease-free who are correctly identified by not meeting the particular FH definition
- Positive predictive value (PPV) – indicates the proportion of individuals who meet the particular FH definition who will actually develop or currently have the disease
- Negative predictive value (NPV) – indicates the proportion of individuals who do not meet the particular FH definition who will remain disease free or do not currently have the disease.

PPV and NPV are influenced by the underlying prevalence of the disease in the population studied – the higher the prevalence, the higher the PPV and the lower the NPV, and vice versa. Sensitivity and specificity are not influenced by disease prevalence. The final metric, area under the summary receiver operator characteristics (SROC) curve and area under the curve (AUC), provides an overall assessment of accuracy of classification. Note that the SROC curve could only be computed if a minimum of three studies had the same FH definition. An AUC of 1.0 indicates a perfectly calibrated test – 100 percent of individuals are correctly classified as affected or unaffected. An AUC of 0.5 indicates that the test as calibrated correctly classifies fifty percent of individuals into affected and unaffected and therefore is no better than chance. An AUC of less than 0.5 suggests the test is worse than chance. The ‘ideal’ calibration of a test (i.e., the ‘best’ FH definition) depends on whether the goal is to prioritize sensitivity (lowest possible chance of missing real cases), specificity (lowest possible chance of false positives), or overall accuracy of classification (the highest AUC).

### Breast Cancer

Four studies were included (see Webtable 1, Appendix C), two with a longitudinal design,3,4 and two cross sectional.5,6 Two studies were conducted in the U.S.,3,6 one in Canada,4 and one in the United Arab Emirates.5 Sample sizes ranged from 1,445 to 115,460. The longest followup periods for the longitudinal studies were 12 months4 and 8 years.3 Please see Webtables 2 and 3 for the methods used to ascertain FH and breast cancer, and the diagnostic criteria used to define the latter.

Family history. Fourdefinitions of ‘positive FH’ based on affected relatives were exam ined in five analyses, all focusing on first degree relatives (1DRs) in some combination. They all fell into Category C or E (see Table 2, Chapter 2); in addition, one study examined parental consanguinity. Three of the studies reported the strength of association between positive FH (i.e., affected relatives) and breast cancer risk in terms of relative risk or odds ratio. Depending on the FH definition used, these ranged from 1.37 to 2.83. A relative risk of 0.66 for the association between parent consanguinity and breast cancer was reported5 but the data in this report were not examined for a FH of affected relatives. These data are presented for each FH definition in Webtable 4, Appendix C.

Predictive accuracy. Figures 3 to 6 present sensitivity and specificity data for these FH definitions.

Figure 3 Breast Cancer, Longitudinal Studies, Sensitivity

Abbreviations: 1DR=first degree relative; CI=confidence interval

Figure 4 Breast Cancer, Longitudinal Studies, Specificity

Abbreviations: 1DR=first degree relative; CI=confidence interval

Figure 5 Breast Cancer, Cross-sectional Studies, Sensitivity

Abbreviations: 1DR=first degree relative; CI=confidence interval

Figure 6 Breast Cancer, Cross-sectional Studies, Specificity

Abbreviations: 1DR=first degree relative; CI=confidence interval

For the longitudinal analyses, the range of sensitivities was 0.06–0.26, and specificities 0.86– 0.95. The range of positive predictive values (PPVs) was 0.01–0.05, and negative predictive values (NPVs) 0.98–0.99, for breast cancer prevalences up to 2.5 percent in the study samples.

For the cross-sectional analyses, the sensitivities were 0.05 and 0.15, with corresponding specificities of 0.97 and 0.90. The PPVs were 0.01 and 0.09 and NPVs were 0.99 and 0.95, for prevalences of 0.7 and 5.4 percent, respectively. It was not possible to calculate AUC.

Conclusion. These analyses were limited by the very few discrete FH definitions available for comparison, and the heterogeneity of the studies in terms of underlying disease frequency in the study samples, length of followup, method of disease ascertainment, and other factors.

With the exception of the parental consanguinity analysis, the definitions of positive FH used in these studies were consistently associated with elevated relative risks (Webtable 4), (i.e., a positive FH of cancer in relatives), at a population level. However defined, it was also a risk factor for future breast cancer incidence (in longitudinal studies) and was positively associated with the presence of current breast cancer (in cross-sectional studies). Within the analyses examined, the most sensitive FH marker for future breast cancer appeared to be ‘at least one affected 1DR’: this is a ‘low complexity’ approach to FH (see Table 2). In the single longitudinal study which used it, this definition correctly identified 26 percent of women who went on to develop breast cancer within 4–8 years (with a false positive rates of 12 percent).3 The proportion of participants with a positive FH defined thus who actually developed breast cancer within 4–8 years was 5 percent. PPV is dependent on underlying disease frequency, which was 2.5 percent. Thus, it can be tentatively concluded that a simple definition of positive FH, based on one 1DR (assumed female) with breast cancer, appeared to be associated with the highest sensitivity for future breast cancer risk within 4–8 years, but that, as always, the predictive ability in practice depends on the breast cancer prevalence in the patient population to whom it was being applied. These observations need to be replicated in further studies which also clarify the contribution of FH information to overall risk prediction based on other established risk factors. Conclusions regarding FH definitions used in a cross-sectional (prevalence screening) approach are not possible because insufficient analyses were available with a range of definitions. However, there would not appear to be a rationale for breast cancer screening triage on the basis of FH in the context of widespread access to effective alternative screening technologies.

Quality assessment. The two longitudinal studies and one of the cross-sectional studies6 scored highly on all or most quality assessment items despite that fact that two of the published reports4,6 did not indicate clearly that the same method of FH ascertainment had been applied to all participants. Overall, these studies were judged to be at low risk of significant bias. One cross-sectional study5 scored less well across almost all items because of incomplete reporting, making it difficult to judge the likelihood of important bias. See Webtable 5, Appendix C.

### Colorectal Cancer

Three studies were included in the colorectal cancer (CRC) analysis (see Webtable 1, Appendix C), one longitudinal (with data derived from two separate original cohort studies, one with male, and the other with female participants),7 and two cross-sectional.8,9 One was conducted in a U.S. population7 one in the U.K,8 and one in several Asian cities.9 Samples sizes ranged from 860 to 134,365. The followup periods reported in the longitudinal study were 14 years for the female cohort and 20 years for the male cohort.7 Please see Webtables 6 and 7, in Appendix C for the methods used to ascertain FH and CRC, and the diagnostic criteria employed for the latter.

Family history. Four definitions of ‘positive FH’ were examined, all focusing on 1DRs and all in Category C (Table 2). One study8 examined multiple definitions within the same dataset and reported analyses by gender, and by age of onset of cancer. All three publications reported the strength of association between positive FH and colorectal cancer risk in terms of RR or OR. Depending on the FH definition used, and the outcome (all disease or premature disease) of these ranged from 1.33 to 5.29. The data by specific FH definition are presented in Webtable 4, Appendix C.

Predictive accuracy. Figures 7 through 10 present sensitivity and specificity data for these FH definitions.

Figure 7 CRC, Longitudinal Studies, Sensitivity

Abbreviations: 1DR=first degree relative; CI=confidence interval; CRC=colorectal cancer; F=female; M=male

Figure 8 CRC, Longitudinal Studies, Specificity

Abbreviations: 1DR=first degree relative; CI=confidence interval; CRC=colorectal cancer; F=female; M=male

Figure 9 CRC, Cross-sectional Studies, Sensitivity

Abbreviations: 1DR=first degree relative; CI=confidence interval; CRC=colorectal cancer; F=female; M=male

Figure 10 CRC, Cross-sectional Studies, Specificity

Abbreviations: 1DR=first degree relative; CI=confidence interval; CRC=colorectal cancer; F=female; M=male

The interpretation of the longitudinal analyses is limited because only one criterion for positive FH is used, (>=1 1DR). Sensitivities of 0.13 and 0.14 were obtained for the male and female cohorts with a specificity of 0.92 for both.

For both cohorts, the PPVs were 0.02 and the NPVs 0.99, for underlying colorectal cancer prevalence of around 1 percent. For the cross-sectional analyses, the range of sensitivities was 0.00 to 0.20, and specificities 0.88 to 1.00. The range of PPVs was 0.00 to 0.07 and NPVs of 0.96 or higher, for overall CRC prevalences ranging from <1 to 4.5 percent. It was not possible to calculate AUC for either the longitudinal or cross-sectional data. The AUC for category C FH definition was 0.64.

Conclusion. These analyses were limited by the relatively few discrete FH definitions available for comparison. The two longitudinal analyses reported in a single report appeared to be fairly homogeneous in terms of participant characteristics, albeit one examined males and one examined females. The results suggest that a simple definition of ‘positive FH’ (>=1 1DR) was associated with an ability to correctly identify around 13–14 percent of cases of CRC arising in the subsequent 16–20 years, with a false positive rate of about 8 percent. However, a PPV of 0.02 would imply that 98 percent of the ‘FH positive’ individuals would be wrongly classified (would not develop CRC). It is likely that some of the latter avoided cancer through screening and the removal of pre-malignant lesions (thus the FH ‘test’ was not strictly ‘wrong’). However, the larger the proportion of the population meeting the FH criterion (around 8 percent in this study), the higher the chance of unnecessary clinical intervention.

In relation to the two cross-sectional studies, a wide range of sensitivities and specificities were observed, due in part to the multiple analyses performed within one dataset,8 making it difficult to discern any pattern across definitions of different complexity. Irrespective of this, the highest PPV was 0.07, suggesting rather low ability of any FH definition to indicate the presence of prevalent CRC.

While these analyses do not, in themselves, suggest the utility of any particular positive FH definition in relation to prediction of or screening for CRC, they are also not sufficient to rule out the possibility of using FH to usefully augment existing predictive or screening strategies.

Quality assessment. All three studies scored highly in relation to uniform methods of ascertaining FH (exposure) and colorectal cancer (outcome). For two studies,7,8 it was possible that knowledge of disease status may have influenced ascertainment of FH, and for all three it was possible that knowledge of FH may have influenced ascertainment of colorectal cancer. The possibility of selection bias through attrition or low response rates could not be ruled out for all three studies. See Webtable 5, Appendix C.

### Prostate Cancer

The prostate cancer analysis was based on six studies (see Webtable 1, Appendix C), four longitudinal10–13 and two cross-sectional.14,15 One study15 reported an analysis of participants in a prospective cohort study, but FH was ascertained at a late stage in the study therefore it was treated as a cross-sectional analysis. Four were conducted in U.S. populations,10,12,13,15 and two in Finnish populations.11,14 The average followup periods for the longitudinal studies ranged from 6.8 to 18 years. Please see Webtables 8 and 9, in Appendix C for the methods used to ascertain FH and prostate cancer, and the diagnostic criteria used.

Family history. Ten discrete definitions of ‘positive FH’ were examined, with at least one falling in each of the categories A-E (Table 2). All studies reported the strength of association between positive FH and prostate cancer risk in terms of RR or OR. Depending on the FH definition used, these ranged from 0.97 to 6.5. The data by specific definition are presented in Webtable 4, Appendix C.

Predictive accuracy. Figures 11 through 14 present the sensitivity and specificity data for the various FH definitions used in these analyses. For the longitudinal analyses, the range of sensitivities was 0.00–0.21, and specificities 0.88–1.00. Excluding one study using mortality as the outcome, the range of PPVs was 0.11–0.26, and NPVs 0.92–0.95, for prostate cancer prevalences up to 8.7 percent. The AUC for category B FH definitions was 0.51 and for category C FH definitions was 0.93.

Figure 11 Prostate Cancer, Longitudinal Studies, Sensitivity

Abbreviations: 1DR=first degree relative; CI=confidence interval

Figure 12 Prostate Cancer, Longitudinal Studies, Specificity

Abbreviations: 1DR=first degree relative; CI=confidence interval

Figure 13 Prostate Cancer, Cross-sectional Studies, Sensitivity

Abbreviations: 1DR=first degree relative; CI=confidence interval

Figure 14 Prostate Cancer, Cross-sectional Studies, Specificity

Abbreviations: 1DR=first degree relative; 2DR=second degree relative; CI=confidence interval

For the cross-sectional analyses, range of sensitivities was 0.01–0.26 and specificities 0.91–1.00. The PPVs were 0.02–0.14 and NPVs 0.96–0.98, for prostate cancer prevalences up to 8.7 percent. The AUC could not be calculated.

Conclusion. A range of definitions of positive FH were examined in these studies, in both predictive and screening contexts. Almost all of the definitions of FH used were associated with positive risk of future disease incidence or current disease presence. However, the definitions examined here appeared, overall, no better than chance in predicting future presence or absence of prostate cancer in the participants studied.

Regarding FH as an approach to identify individuals who may currently be affected (cross-sectional studies), the sensitivities and PPVs were uniformly low. The highest sensitivity was 26 percent for presence of cancer and the highest PPV 14 percent in a study where many participants were already aware of their cancer diagnosis. Further studies to clarify the information gained from FH information (and specific definitions) might be warranted if it added value when used in conjunction with other screening strategies.

Quality assessment. In general, the longitudinal studies scored high on quality assessment items, with the exception of one13 in which key methodological details were not reported. For the two cross-sectional studies, the possibility that knowledge of FH influenced ascertainment of prostate cancer outcomes could not be ruled out, and both were possibly subject to selection bias through low response rates. See Webtable 5, Appendix C.

### Coronary Heart Disease

Eight studies were included in the coronary heart disease (CHD) analysis (see Webtable 10, Appendix C), five longitudinal16–20 and three cross-sectional.21–23 Four were conducted in U.S. populations,16,20,22,23 (one in American Filipina women23) and one each in Pakistan,21 Sweden,17 Finland,18 and Denmark.19 One of the longitudinal studies16 reported analyses based on two individual cohort studies, one in men and one in women. The average followup periods for the longitudinal studies ranged from 6.2 to 19.6 years. Please see Webtables 11 and 12 in Appendix C for the methods used to ascertain FH and coronary heart disease, and the various definitions and diagnostic criteria used.

Family history. Seventeen discrete definitions of ‘positive FH’ were analyzed, with at least one in each of the categories B-E. All studies except one20 reported the strength of association between positive FH and coronary heart disease risk in terms of RR or OR. Depending on the FH definition used, these ranged from 0.93 to 6.2. The data by specific definition are presented in Webtable 4, Appendix C.

Predictive accuracy. Figures 15 through 18 present the sensitivity and specificity data for these definitions of FH. For the longitudinal analyses, the range of sensitivities was 0.03–0.51 and specificities 0.66–0.98. The range of PPVs was 0–0.13 and NPVs 0.66–0.98, for CHD prevalences up to 10.4 percent. The definitions were all category B and the AUC for this category was 0.58.

Figure 15 CHD, Longitudinal Studies, Sensitivity

Abbreviations: CHD=coronary heart disease; CI=confidence interval; F=female; M=male

Figure 16 CHD, Longitudinal Studies, Specificity

Abbreviations: CHD=coronary heart disease; CI=confidence interval; F=female; M=male

Figure 17 CHD, Cross-sectional Studies, Sensitivity

Abbreviations: 1DR=first degree relative; 2DR=second degree relative; CHD=coronary heart disease; CI=confidence interval F=female; M=male

Figure 18 CHD, Cross-sectional Studies, Specificity

Abbreviations: 1DR=first degree relative; 2DR=second degree relative; CHD=coronary heart disease; CI=confidence interval; F=female; M=male

For the cross-sectional analyses, the range of sensitivities was 0.07–0.70 and specificities 0.53–0.98. The range of PPVs was 0.08–0.31, and NPVs 0.83–0.98, for CHD prevalences up to 20.7 percent. The AUC could not be estimated for cross-sectional studies.

Conclusion. The longitudinal analyses suggest an association between broadness and narrowness of a minimum FH definition and sensitivity and specificity although these simple definitions as a whole classified the future CHD risk correctly for only 58 percent of participants. The PPVs were almost all below 10 percent. This means that, if practice populations are similar to those analyzed here, at least 90 percent of individuals meeting any of the FH definitions would be incorrectly classified as high risk for developing CHD. The highest disease prevalence in the cohorts studied was around 10 percent, but in some analyses, more than a third of the participants met the FH definition. Generally, similar PPVs were obtained for the definitions examined in the cross-sectional studies, although the analyses were dominated by a single study.22

Overall, the value of the most highly predictive FH definitions needs to be assessed in the light of the predictive ability of other established factors such as blood pressure, lipid profiles, or anthropometric measures, and in the context of the risks and costs of available interventions to reduce risk, to determine whether it is likely to add significant information value in routine clinical settings. The underlying prevalence of disease in the patient population is an important factor which needs to be taken into account.

Quality assessment. The five longitudinal studies generally scored fairly high on quality assessment items, with the exception of one17 where inadequate reporting made it impossible to assess four of the six items. For all three cross-sectional studies, the possibility of awareness of FH status influencing reporting of presence or absence of coronary heart disease, and vice versa, could not be ruled out. Also, sample selection bias could not be excluded because of non-probability sampling methods21,23 and/or sub-optimal response rates. See Webtable 13, Appendix C.

### Stroke

Three studies were included (see Webtable 10, Appendix C) in the stroke analysis, all longitudinal in design.24–26 One was conducted in a U.S. population,24 one in Finland,25 and one in Japan.26 The average followup periods ranged from 5 to 19 years, and analyses focused on clinically apparent stroke only. Please see Webtable 14 for the methods used to ascertain FH and stroke outcomes, and the diagnostic criteria used.

Family history. Three separate definitions of ‘positive FH’ were examined, all relating to parental illness and all in category B (Table 2). All three studies reported the strength of association between positive FH and stroke risk in terms of relative risk. Depending on the FH definition used, these RRs ranged from 0.73 to 2.17. The data by specific definition are presented in Webtable 4, Appendix C.

Predictive accuracy. Figures 19 and 20 present the sensitivity and specificity data for the FH definitions in these studies. The range of sensitivities was 0.05–0.33, and specificities 0.71–0.98. The range of PPVs were 0.02–0.08 and NPVs 0.96–0.98, for prevalences of stroke up to 3.9 percent. The AUC for these category B FH definitions was 0.43.

Figure 19 Stroke, Longitudinal Studies, Sensitivity

Abbreviations: CI=confidence interval; F=female; M=male

Figure 20 Stroke, Longitudinal Studies, Specificity

Abbreviations: CI=confidence interval; F=female; M=male

Conclusion. TheFH definitions available for analysis we re restricted to parental FH only, and many of the data were derived from a single study25 which focused on stroke before the age of 60. The data support a negative association between strictness of FH and magnitude of sensitivity. However, the PPVs suggest that using any of these FH definitions in isolation from knowledge of other risk factors, could lead to over 90 percent of ‘FH positive’ individuals being wrongly identified as being at higher risk. This is due to the overall low frequency of stroke in the study populations over the time periods studied.

Quality assessment. Two25,26 scored highly on all or almost all quality assessment items. The assessment of the third24 was limited by lack of reporting in relation to four of six quality criteria. The possibility of awareness of FH influencing ascertainment of stroke outcome could not be ruled out, and it was not clear whether the same method of FH collection was applied to all participants. The rate of attrition over several years of followup was unclear. See Webtable 13, Appendix C.

### Diabetes

Seventeen studies were included in this analysis (see Webtable 15, Appendix C). Five were longitudinal27–31 and 12 were cross-sectional.32–43 In addition, the findings of a cross-sectional study63 designed expressly to examine different FH definitions are included, although the data were not presented in a way which permitted their inclusion in the calculations below.

Five studies were conducted in U.S. populations,29,31,33,37,40 including one in Japanese Americans29 and one in native Alaskans.33 Two studies were conducted in Norwegian populations,27,38 and two in the Netherlands.28,41 Single studies were conducted in the United Kingdom,30 India,32 Pakistan,42 Nigeria,34 Israel,35 Jordan,43 Greece,36 and Sweden.39 The average followup periods for the longitudinal studies ranged from 5 to 22 years, except for one study which examined disease risk in offspring (mean offspring age 54 years) of the original Framingham cohort.31 Sample sizes ranged from 454 to 64,498. Please see Webtable 15 in Appendix C for the methods used to ascertain FH and diabetes, and the diagnostic criteria used.

Family history. Twenty different definitions of ‘positive FH’ were analyzed, in categories B-E (Table 2). All studies except one42 reported the strength of association between positive FH and diabetes risk for at least one definition in terms of relative risk, odds ratio, or similar metric. Depending on the FH definition used, these ranged from 1.53 to 14.83. The data by specific definition are presented in Webtable 4, Appendix C.

Predictive accuracy. Figures 21 through 24 present the sensitivity and specificity data for these definitions of FH. For the longitudinal analyses, the range of sensitivities was 0.02–0.47, and specificities 0.79–1.0. The range of PPVs was 0.02–0.38, and NPVs 0.86–0.99, for underlying diabetes prevalences up to 16.2 percent. (Webtable 16) The AUC for category C was 0.43.

Figure 21 Diabetes, Longitudinal Studies, Sensitivity

Abbreviations: 1DR=first degree relative; CI=confidence interval; F=female; M=male

Figure 22 Diabetes, Longitudinal Studies, Specificity

Abbreviations: 1DR=first degree relative; CI=confidence interval; F=female; M=male

Figure 23 Diabetes, Cross-sectional Studies, Sensitivity

Abbreviations: 1DR=first degree relative; 2DR=second degree relative; CI=confidence interval;

Figure 24 Diabetes, Cross-sectional Studies, Specificity

Abbreviations: 1DR=first degree relative; 2DR=second degree relative; CI=confidence

For the cross-sectional analyses, (Webtable 17) the range of sensitivities was 0.02–0.83 and specificities 0.44–0.99, for prevalences up to 17.4 percent. The AUC figures for category B, C, and D definitions were 0.69, 0.71, and 0.64, respectively.

A further paper63 reported the results of applying a three-level, FH-based, risk stratification system to representative U.S. adult survey data. The definitions for the risk strata are summarized in Table 3. The overall prevalence of diabetes in the survey population was 6.6 to 6.7 percent, and ORs of 2.8 and 7.5 were obtained for the moderate and high definitions respectively. The FH definitions used for the stratification system are presented in Table 3 while the sensitivities, specificities, and predictive values for the increased (moderate plus high) and high risk categories obtained in this analysis are presented in Table 4.

Table 3 Three-level risk stratification system63

Stratum | Definition
High | ≥2 parents and/or siblings with diabetes or ≥1 parent or sibling and 2 grandparents with diabetes from the same lineage
Moderate | One 1DR and one 2DR with diabetes or One 1DR with diabetes or Two 2DRs with diabetes from the same lineage
Average | No more than one 2DR with diabetes

Abbreviations: 1DR=first degree relative; 2DR=second degree relative

Table 4 Discriminatory accuracy metrics associated with risk stratification system63

Risk level | Sensitivity | Specificity | PPV | NPV
All adults (20–85)
High | 0.19 | 0.94 | 0.10 | 0.97
Moderate + high | 0.48 | 0.73 | 0.05 | 0.98
Older adults (45–85)
High | 0.21 | 0.93 | 0.15 | 0.95
Moderate + high | 0.46 | 0.70 | 0.08 | 0.96

Abbreviations: NPV=negative predictive value; PPV=positive predictive value

Conclusion. A large range of FH definitions were examined in these studies, ranging from very simple to very complex. Almost all indicated a positive association between FH and risk of diabetes. The studies were very heterogeneous in terms of how diabetes was defined, the underlying diabetes risk in the population, length of followup, and other characteristics. Taken overall, the analyses suggest that using FH to predict future risk of diabetes may have some utility, and that category B definitions (specifying 1–2 affected relatives) achieve higher overall discriminatory accuracy than category C definitions. However, the relationship between diabetes prevalence and PPV should be taken into account.

FH may be a useful factor to take into account in triaging individuals for diabetes screening (i.e., screening for undetected prevalent disease). The AUC figures suggest that no further discriminatory accuracy is obtained by going beyond simple FH definitions, (i.e., limited enquiry about 1DRs only). If these findings were replicated, it is possible that meeting a simple FH criterion might be sufficient to merit a second stage screening test such as fasting glucose, where health care resource constraints present limits to universal screening using clinical tests. Again, the underlying prevalence of diabetes in the population should be taken into account as this affects the predictive value of any FH definition.

Quality assessment. The longitudinal studies generally scored highly on quality assessment items. For one,30 it was possible that ascertainment of diabetes may not have been blinded to FH status, and in two studies28,31 this was not adequately reported. One longitudinal study had more than 20 percent attrition over 4 years;28 the participants were elderly men, the attrition is likely to have reflected mortality, and a higher rate of diabetes incidence in those lost cannot be excluded. Two other longitudinal studies failed to report data on attrition.27,29 Almost all of the cross-sectional studies were subject to possible exposure information bias, in that awareness of disease status may have influenced FH reporting. Similarly, many cross-sectional studies included self-report of diabetes in their outcome definition, which was not independent of awareness of FH status. These issues appeared to have been appropriately controlled for, in only one cross-sectional study.39 The other major quality issue in the cross-sectional studies was the possibility of selection bias, through definite or possible non-probability sampling,36,39 and definite or possible sub-optimal participation rates (all but two studies32,38). See Webtable 18, Appendix C.

### Asthma and Atopic Disease

The asthma and atopic disease analysis was based on 17 publications but only 16 studies are presented, four longitudinal,44–46,48 eleven cross-sectional.2,49–58 One of the cross-sectional studies59 presented a followup analysis of a random sample of an initial cross-sectional analysis58 and was treated as cross-sectional (see Webtable 19, Appendix C); the data for these two studies were evaluated separately. Six studies44–46,48,52,57 analyzed data relating to atopic disease in general, of which two44,52 also included separate analyses for asthma. The remaining ten studies 2,49,51–56,58,59 presented data relating to asthma alone.

Three were conducted in U.S. populations,49,52,54 two in Germany,45,46 two in Brazil (including two reports of the same cohort),48,58,59 and one each in Qatar,51 Turkey,55 Japan,56 Poland,57 Sweden,53 Norway,2 Spain,50 and the United Kingdom.44

The four longitudinal studies all followed birth cohorts, one to 12 months,48 two to 2 years,44,45 and one to four years.44

Most of the cross-sectional analyses focused predominantly on children and young adults (up to 20 years of age), with only two conducted in adult populations, examining asthma only.2,53 By definition, all of the asthma studies examined FH of asthma; one of the longitudinal studies44 also examined FH of atopy as a risk factor for asthma, so for completeness these data were included in this report. Please see Webtables 20 through 23 in Appendix C for the methods used to ascertain FH and the outcomes of asthma and atopy, and the diagnostic criteria employed.

Family history. Ten separate definitions of ‘positive FH’ were employed, in categories B-D (Table 2). For the studies of atopy outcome, relative risks/odds ratios ranged from 0.52 to 11.2. For the studies of asthma outcome, relative risks/odds ratios from 1.06 to 12.15 were observed. The data by specific definition are presented in Webtable 4, Appendix C.

Predictive accuracy. Figures 25 through 32 present the sensitivity and specificity data for these definitions of FH, for the outcomes atopy and asthma separately. For the longitudinal analyses of atopy, the range of sensitivities was 0.15–0.64, and specificities 0.44–0.91. The range of PPVs was 0.25–0.46 and NPVs 0.7–0.84, for atopy prevalences up to 38.6 percent. The AUC could not be estimated.

Figure 25 Atopy, Longitudinal Studies, Sensitivity

Abbreviations: 1DR=first degree relative; CI=confidence interval; F=female; M=male; y=years

Figure 26 Atopy, Longitudinal Studies, Specificity

Abbreviations: 1DR=first degree relative; CI=confidence interval; F=female; M=male; y=years

Figure 27 Atopy, Cross-sectional Studies, Sensitivity

Abbreviations: CI=confidence interval; F=female; M=male; y=years

Figure 28 Atopy, Cross-sectional Studies, Specificity

Abbreviations: CI=confidence interval; F=female; M=male; y=years

Figure 29 Asthma, Longitudinal Studies, Sensitivity

Abbreviations: CI=confidence interval; 1DR=first degree relative; F=female; M=male; y=years

Figure 30 Asthma, Longitudinal Studies, Specificity

Abbreviations: CI=confidence interval; 1DR=first degree relative; F=female; M=male; y=years

Figure 31 Asthma, Cross-sectional Studies, Sensitivity

Abbreviations: 1DR=first degree relative; CI=confidence interval; F=female; M=male; y=years

Figure 32 Asthma, Cross-sectional Studies, Specificity

Abbreviations: 1DR=first degree relative; CI=confidence interval; F=female; M=male; y=years

For the cross-sectional analyses of atopy, the range of sensitivities was 0.23–0.48, and specificities 0.56–0.83. The range of PPVs was 0.28–0.52 and NPVs 0.68–0.74, for atopic disease prevalences up to 36.2 percent. The data did not permit calculation of AUC figures.

For the longitudinal asthma analyses, the range of sensitivities was 0.18–0.69 and specificities 0.43–0.91. The range of PPVs was 0.17–0.25 and NPVs 0.86–0.89, for an asthma prevalence of 15.9 percent. The AUC values could not be estimated. For the cross-analyses, the range of sensitivities was 0.04–0.76 and specificities 0.46–0.99. For the childhood studies only, the range of PPVs was 0.08–0.51 and NPVs 0.82–0.94, for asthma prevalence up to 19.8 percent. For the two adult studies, the PPVs were 0.07 and 0.13 and NPVs 0.96 and 0.98, respectively, for prevalences of asthma of 3.1 and 5.5 percent. The AUC values for category B and C definitions were 0.73 (father positive) and 0.77 (mother positive) and 0.66, respectively.

Conclusion. With the exception of two studies, all of the asthma and atopy analyses examined prediction of disease in children and young people. Positive FH definitions were almost entirely based on affected 1DRs only. The clinical utility of using any FH definition to predict future risk onset of asthma or atopic disease in infants or children depends on the availability of preventive interventions, although there may be educational benefits for parents with respect to early recognition of symptoms in susceptible children. The utility of choosing of FH definition as a screening tool for current allergy or asthma depends on the availability, cost, and risks of other screening or diagnostic modalities.

Quality assessment. Three of the four longitudinal studies scored well across four of the six quality assessment items, the fourth46 meeting three criteria. The issues of concern consistent across all four were the possibility of ascertainment of atopy or asthma outcome being influenced by awareness of FH status, and the possibility for differences in method of capture of FH information.46,48 Followup rates were suboptimal for one study,45 and not adequately reported in another.46 An issue across all the cross-sectional studies was the possibility of awareness of FH influencing disease definition or ascertainment, and/or awareness of disease status influencing FH reporting. In all, except four reports of three independent studies,51,55,58,59 the possibility of selection bias through non-probability sampling and/or sub-optimal participation rates could not be dismissed. See Webtable 24, Appendix C.

### Mental Illness

Two papers contributed to the analysis of mental illness, (see Webtable 25, Appendix C) one longitudinal,60 and one cross-sectional.62 Both presented data on prediction of major depressive disorder (MDD) and one60 also examined any mood disorder as an outcome condition, considered a more appropriate measure in childhood and adolescence. Both examined outcomes according to DSM-IV criteria, to 26 years of age and were conducted in U.S. populations.

The longitudinal study60 followed up the third generation of a family study in which the grandparents of the participants formed the inception cohort. The second study62 was based on a single-age cohort followed from childhood to age 26, which was treated as a cross-sectional analysis because the FH was ascertained at the followup point. Please see Webtables 26 through 28 in Appendix C for the methods used to ascertain FH and the outcomes of MDD and mood disorder, and the specifics of the diagnostic criteria used.

Family history. Four definitions of ‘positive FH’ were examined, all in category B (Table 2). For the analyses of MDD outcome, relative risks/odds ratios ranged from 1.84 to 2.9. For the analysis of mood disorder outcome, a single relative risk of 2.8 was reported. The data by specific definition are presented in Webtable 4, Appendix C, along with data on disease frequency and predictive values.

Parental plus grandparental MDD was associated with a the relative risk of 2.80 for any mood disorder, and 2.33 for MDD in the third generation.60 Odds ratios of 1.84 and 2.88 were found for the association between parental depression and sibling depression, respectively, in the cross-sectional study.62

Predictive accuracy. Figures 33 through 38 present the sensitivity and specificity data for these studies, for the outcomes MDD and mood disorder, respectively. For the longitudinal analyses, the range of sensitivities was 0.72–0.83 and specificities 0.40–0.59; for any mood disorder, the range of sensitivities was 0.73–0.83 and specificities 0.42–0.63. The range of PPVs for MDD was 0.14–0.18 and NPVs 0.92–0.95; for mood disorder, the corresponding values were 0.24–0.31 and 0.89–0.93. The overall prevalence of MDD for this study was 11.2 percent, and for any mood disorder was 18.6 percent. A relatively high proportion of participants met at least one of the definitions for positive FH (44.1–62.7 percent), reflecting the constitution of the original cohort.

Figure 33 MDD, Longitudinal Studies, Sensitivity

Abbreviations: CI=confidence interval; F=female; M=male; MDD=major depressive disorder; y=years

Figure 34 MDD, Longitudinal Studies, Specificity

Abbreviations: CI=confidence interval; F=female; M=male; MDD=major depressive disorder; y=years

Figure 35 MDD, Cross-sectional Studies, Sensitivity

Abbreviations: CI=confidence interval; F=female; M=male; MDD=major depressive disorder; y=years

Figure 36 MDD, Cross-sectional Studies, Specificity

Abbreviations: CI=confidence interval; F=female; M=male; MDD=major depressive disorder; y=years

Figure 37 Mood, Longitudinal Studies, Sensitivity

Abbreviations: CI=confidence interval; F=female; M=male; y=years

Figure 38 Mood, Longitudinal Studies, Specificity

Abbreviations: CI=confidence interval; F=female; M=male; y=years

The cross-sectional analyses produced sensitivities of 0.12 and 0.24 and specificities of 0.85 and 0.96, respectively. The PPVs were 0.33 and 0.45, and NPVs were 0.79 and 0.78, respectively, for a prevalence of MDD of 23.2 percent.

It was not possible to calculate AUC values for any of the mental illness analyses.

Conclusion. The analyses were limited to two studies only, both of which had higher than expected frequency of MDD or mood disorder. In one this was a result of study design,60 and in the other this may reflect participant selection bias.62 On the face of it, the findings of the longitudinal study appear to suggest that FH definitions based on parents could predict around three fourths of cases of major depression or mood disorder in offspring up to the age of 25, although the false positive rate is rather high at 50 percent or more. The clinical utility of PPVs of around 15 percent for MDD and 25–30 percent for mood disorder depends on the possibility of preventive intervention in childhood or adolescence, and the more general net benefits of being aware of an individual’s susceptibility. Whether this level of predictive validity would be obtained in lower prevalence populations is questionable, and lower NPVs could be associated with stigmatization and unnecessary clinical intervention. The uncommon design of this study (three generation cohort) means that the findings cannot automatically be extrapolated to general populations, and the ascertainment of FH was not typical of a primary care consultation, where patient self-reporting would likely be less accurate and less complete. In contrast, the cross-sectional study was initially established as a population-based study although fewer than half of the original participants were included in the analysis considered here. The prevalence of major depression was high (almost a quarter of the study group); like the other study, the method of assessing FH was likely more complete and detailed than would be obtained in a primary care consultation based on patient self-reporting. For the two FH definitions examined in this study, it is not possible to draw conclusions regarding the value of using FH alone to screen for presence of major depression.

Taking all of these issues into account, it is difficult to extrapolate the findings to typical primary care settings. If similar predictive values were obtained in studies conducted in less selected populations and with more typical data collection procedures, parental history of depression might offer useful information relating to identifying youth and young adults at risk.

Quality assessment. The longitudinal study60 scored high across all quality assessment criteria, likely reflecting its unusual prospective multi-generational design. The cross-sectional study62 (which was in fact a cross-sectional analysis of an original prospective cohort study) was assessed as being potentially prone to bias in relation to independence of assessment of FH and disease outcome, and selection bias through sub-optimal participation rate at the point the analysis was performed. See Webtable 29, Appendix C.

## Question 2: What is the Accuracy of the Family History, and Under What Conditions Does the Accuracy Vary?

### General Approach to Evaluating Accuracy

Accuracy of a test (in this case reporting of FH) represents the proportion of all test results that are true (both positive and negative outcomes). If individuals reporting FH were 100 percent accurate, they would correctly identify all relatives with the disease and all those without the disease. A number of metrics may be used to convey accuracy and from these, sensitivity and specificity are not influenced by the underlying prevalence of the characteristic of interest in the population (in this case, a positive FH). We therefore aimed to present sensitivity and specificity where this is reported in, or could be calculated from, eligible papers as the metric reflecting accuracy of self-reporting. Where this was not available, we reported other metrics of accuracy such as percent agreement.

In this systematic review, we considered “reporting of FH by the informant” as the “index test”, and required that there be comparison to a “gold standard” (representing the real or true disease state). We use the term informant to reflect that in some instances the person reporting family history may be a proxy respondent who knows the individual for whom family history is being evaluated. In this context, sensitivity indicates how accurate informants are at identifying relatives who truly have the disease. If reporting is highly sensitive, only a few relatives with the disease will be reported as disease-free. Conversely, if reporting is highly specific, only a few relatives who are truly disease-free are misreported as having cancer. It is likely that accuracy of reporting one’s FH will be influenced by factors relating to both the informant and the relatives; the method of capturing the FH data is also an important consideration.

As there is no clear “gold standard” against which the accuracy of self-reporting of FH is evaluated, we decided to accept the following reference standards for the presence or absence of disease in the 1DRs and 2DRs, or higher, of the informant: 1) the relative’s medical record, 2) confirmation of status by the relative’s physician, 3) death certificate, 4) disease registry, and 5) direct confirmation by the relative in question. Not all research databases that contain medical records were eligible as sources of verification for this review as we excluded studies that did not provide complete accuracy information including those databases that provided information on the number of true positives only. Data from these studies would not assist us in understanding the true accuracy of respondents providing their FH.

A total of 37 publications evaluated the accuracy of reporting FH, were eligible for data extraction, and reported data separately for spouses and genetic relatives. The majority of papers (n=16) evaluated accuracy of reporting cancer FH, in persons who had cancer (breast, ovarian, colorectal, prostate, lymphoma, melanoma, Ewing’s or mixed cancers) or who were being screened for cancer. There were 12 studies that evaluated accuracy of reporting FH for mental health disorders and these included persons with mood disorders, mixed disorders, and schizophrenia. The remaining studies evaluated persons with Parkinson’s disease (n=2), persons with cardiovascular/hypertension related problems (n=3) or persons with diabetes (n=2) and two studies123,124 with populations from longitudinal cohorts that had mixed diseases (diabetes, hypertension, cardiovascular disease, and asthma).

### Accuracy of Self-reporting of Cancer FH

Population. A total of 16 studies evaluated accuracy of reporting cancer FH. These studies recruited informants (probands) with breast cancer,91–94 colorectal cancer,95–97 prostate cancer,98,99 ovarian cancer,100 mixed cancers (breast, ovarian, colorectal),101,102 Ewing’s Sarcoma,103 lymphoma,104 melanoma,105 and unspecified cancer.106

Nine studies were case series in design and seven were case control studies for probands with breast,91 colorectal,95–97 ovarian,100 and prostate98 cancers, and lymphoma.104 In the case-referent studies, controls were derived from a range of sources including: the general population (age-matched),91,100,104 informants’ spouses and general practice rosters,97 patients who had undergone colonoscopy but were free of polyps,96 and healthcare administration databases.95,98 The case series studies, all collected FH from subjects with cancer who were recruited from specialized clinics or registries. One study103 evaluated a sample of deceased relatives of the probands; the challenges and potential errors of death certification and registries were the focus of this paper.

Method of family history collection in informants/probands. The methods of cancer FH collection varied. Six studies used face to face interviews,91,95,97,99,103,106 six used mailed surveys,92,94,96,98,102,105 three used telephone interviews,93,101,104 and one study did not report the mode of collection.103 Generally, the specific type of FH questions were not specified, but probed information predominately related to degree of the relative.

Method of disease verification in informants/relative. The methods used to verify relatives’ cancer status were primarily multimodal and included: review of medical records (including cancer registry) and death registry;92,94,103,106 face to face interview or postal survey of relatives;101 postal survey alone;96,105 and contact with physician of deceased relative.99 Three studies91,98,102 used medical records alone, and five studies used linkage with cancer registry alone.93,95,97,100,104

Disease status was verified in both affected and unaffected relatives in all but five studies.91,94,99,102,105

Study outcomes. Some studies examined only specific can cer family histories, while others examined all cancers of interest. Four studies95,97,100,104 examined reporting of any type of cancer in relatives while the remaining studies examined cancers that matched that of the probands. Tables 5 to 9 show the findings according to the cancer reported in the relatives; we show the major cancers identified in (Q1) which include breast, ovarian, colorectal, and prostate (other cancers were reported much less frequently). We also include the three studies evaluating lymphoma,104 melanoma,105 and unspecified cancers.106

Table 5 Accuracy of self-reporting of FH for cancer in studies that verified the status for breast cancer in relatives

Study | Population/Design/Sample Size | Index Test (FH) Reference Standard | Accuracy
| | | Sensitivity(95%) a/a+c; value[ ] | | Specificity(95%) d/ b+d; value [ ]
Breast Cancer in Relatives (Affected and Unaffected)
Anton-Culver93 1996 U.S. | Consecutive case series (n=359): female breast cancer probands from either a population based or cancer registry | Index Test: Telephone interview (1DRs and 2DRs) Reference Standard: Cancer registry | 54/60; [0.90] (0.79–0.96) | | 364/369; [0.98] (0.97–1.00)
Chang104 2006 Sweden | Cases (n=1508): lymphoma cancer probands from cancer registries, hospitals, and clinics; Controls (n=1229): randomly sampled from the population | Index Test: Telephone interview (1DR) Reference Standard: Cancer registry | Cases: [0.73] (0.70–0.75) Controls: [0.72] (0.69–0.74) | | Cases: [0.99] (0.98–0.99) Controls: [0.99] (0.98–1.00)
Kerber95 1997 U.S. | Cases (n=125): colon cancer probands from DARCC study health administration database Controls (n=206): population based from DARCC health administration database | Index Test: Personal interview (1DR and 2DR) Reference Standard: Utah population health database; Cancer registry | Cases: 11/13; [0.85] (0.55–0.98) κ=0.73<>(0.55–0.90) Controls: 18/22; [0.82] (CI NR)^ κ=0.58 (0.44–0.71) | | Cases: 107/112; [0.95] (0.90–0.98) Controls: 167/184; [0.91] (CI NR)^
Soegaard100 2008 Denmark | Cases (n=579 ): female ovarian cancer probands recruited from gynecological departments; Controls (n=1,564): Population based from civil registry | Index Test: Personal interview (1DR) Reference Standard: Cancer registry | Case [0.89] (0.81–0.97); κ=0.85 (0.79–0.92) Control [0.94] (0.90–0.98); κ=0.89 (0.85–0.93) | | Case [0.99] (0.99–1.00) Control [1.00] (0.99–1.00)
Ziogas101 2003 U.S. | Probands with breast (n=670), ovarian (n=123) and colorectal (n=318 both male and female) cancer from clinic based family registries | Index Test: Telephone interview (1DR, 2DR, 3DR) followed by mailed GRIS pedigree Reference Standard: 1) Medical records or 2) Self-reporting from relatives or 3) Death certificates of deceased relatives | 188/197; [0.95] (0.91–0.98) | | 850/873; [0.97] (0.96–0.98)
Breast Cancer in Relatives (Affected only)
Ereola92 2000 Finland | Probands (n=NR) with breast cancer: a) diagnosed when <40 y b) patients with bilateral disease, c) unselected for age and laterality | Index Test: Mailed questionnaire Reference Standard: 1) Genealogy confirmed by church parish registries 2) Hospital records 3) Cancer registry | % Cases Reported | | % Cases Reported Correctly
Ereola92 2000 Finland | Probands (n=NR) with breast cancer: a) diagnosed when <40 y b) patients with bilateral disease, c) unselected for age and laterality | Index Test: Mailed questionnaire Reference Standard: 1) Genealogy confirmed by church parish registries 2) Hospital records 3) Cancer registry | 1DR | 100 | 95
Ereola92 2000 Finland | Probands (n=NR) with breast cancer: a) diagnosed when <40 y b) patients with bilateral disease, c) unselected for age and laterality | Index Test: Mailed questionnaire Reference Standard: 1) Genealogy confirmed by church parish registries 2) Hospital records 3) Cancer registry | 2DR | 99 | 96
Ereola92 2000 Finland | Probands (n=NR) with breast cancer: a) diagnosed when <40 y b) patients with bilateral disease, c) unselected for age and laterality | Index Test: Mailed questionnaire Reference Standard: 1) Genealogy confirmed by church parish registries 2) Hospital records 3) Cancer registry | 3DR | 61 | 94
Ereola92 2000 Finland | Probands (n=NR) with breast cancer: a) diagnosed when <40 y b) patients with bilateral disease, c) unselected for age and laterality | Index Test: Mailed questionnaire Reference Standard: 1) Genealogy confirmed by church parish registries 2) Hospital records 3) Cancer registry | 4DR | 23 | 100
Ereola92 2000 Finland | Probands (n=NR) with breast cancer: a) diagnosed when <40 y b) patients with bilateral disease, c) unselected for age and laterality | Index Test: Mailed questionnaire Reference Standard: 1) Genealogy confirmed by church parish registries 2) Hospital records 3) Cancer registry | 5DR | 17 | 100
Ereola92 2000 Finland | Probands (n=NR) with breast cancer: a) diagnosed when <40 y b) patients with bilateral disease, c) unselected for age and laterality | Index Test: Mailed questionnaire Reference Standard: 1) Genealogy confirmed by church parish registries 2) Hospital records 3) Cancer registry | Total | 87 | 95
King99 2002 U.S. | Probands with prostate cancer (n=143) from the cancer centers | Index Test: Interview Reference Standard: Medical records and death certificates | Accuracy rates: Documented (%); 97.6% Accurate (%) − 95.0%
Parent91 1995 Canada | Cases (n=414): probands with breast cancer enrolled in study on study on nutritional factors in breast cancer Controls (n=429): population based | Index Test: Personal interview (1DR). Reference Standard: Medical records | Mean error in reported age minus confirmed age of diagnosis Cases: 0.24 yrs (95% CI, −0.60–1.08) Controls : −0.03 yrs (95% CI, - 0.88=0.82) Some data to suggest that more errors in reporting of age of diagnosis are associated with >70 yrs of respondent, and >10 yrs since diagnosis of the relative
Schneider94 2004 U.S. | Two series of subjects undergoing genetic testing for having a relative with a) LFS (n=32), or b) HBOCS (n=52) Some of the HBOCS had breast cancer | Index Test: Self-reporting questionnaire (up to 4 generations) Reference Standard: 1) Medical records or 2) death certificates | Accuracy of any cancer diagnoses HBOCS cohort=78% Accuracy of any cancer diagnoses by LFS cohort=52% Accuracy of breast cancer report=96% Accuracy of ovarian cancer report=74% Accuracy of other LFS related cancers=55%
Sijmons102 2000 Netherlands | Retrospective analysis of tumor reports from counselees on 120 families in a medical genetics clinic | Index Test: Self-reporting questionnaire followed by interview Reference Standard: 1) Medical records 2) Contact with relatives | Accuracy rate for cancer: Breast 93% Colorectal 89% Ovarian 71% Other 63% All types 78%

Abbreviations: 1DR=first degree relative; 2DR=second degree relative; 3DR=third degree relative; 4DR=fourth degree relative; 5DR=fifth degree relative; BC=breast cancer; CI=confidence interval; DARCC= Diet, Activity and Reproduction in Colon Cancer; FH=family history; GRIS=Genetics Registry System; HBOCS=hereditary breast-ovarian cancer syndrome; LFS=Li-Fraumeni Syndrome; n=number of subjects; NR=not reported; y=years

Table 6 Accuracy of self-reporting of FH for cancer in studies that verified the status for colorectal cancer in relatives

Study | Population/Design/Sample size | Index Test (FH) Reference Standard | Accuracy
| | | Sensitivity(95%) a/a+c; value[ ] | Specificity(95%) d/ b+d; value [ ]
Colorectal Cancer in Relatives (Affected and Unaffected)
Aitken96 1995 Australia | Cases (n=74): probands with colorectal cancer Controls (n=163): Recruited from primary care setting who had undergone colonoscopy | Index Test: Mailed survey (1DR) Reference Standard: 1) Medical record 2) Death certificates | 70/81; [0.86] (0.77–0.93) | 219/239; [0.92] (0.87–0.95)
Chang104 2006 Sweden | Cases (n=1,508): lymphoma cancer probands from cancer registries, hospitals, and clinics; Controls (n=1,229): randomly sampled from the population | Index Test: Telephone interview (1DR) Reference Standard: Cancer registry | In any 1DRs: Cases: [0.48] (0.46–0.51) Controls: [0.53] (0.50–0.55) | In any 1DRs: Cases: [0.99] (0.99–1.00) Controls: [0.99] (0.99–1.00)
Kerber95 1997 U.S. | Cases (n=125): colon cancer probands from DARCC study health administration database Controls (n=206): population based from DARCC health administration database | Index Test: Personal interview (1DR and 2DR) Reference Standard: Utah population health database; Cancer registry | Cases: 11/17; [0.65] (0.38–0.86) Controls: 13/16; [0.81] (CI NR)^ | Cases: 98/108; [0.91] (0.84–0.95) Controls: 178/190; [0.94] (CI NR)^
Mitchell97 2004 U.K. | Cases (n=199) probands with colorectal cancer Controls (n=133): recruited from general practice lists in the same county and some spouses of probands | Index Test: Personal interview by genetics nurse (1DR, 2DR, 3DR) Reference Standard: Cancer registry | Cases: 30/53; [0.57] (0.43–0.69) 1DRs [0.57] (0.43–0.69) 2DRs [0.271] (0.17–0.41) Controls: 1DRs [0.53] (0.31–0.74) 2DRs [0.33] (0.19–0.51) | Cases: 1256/1269; [0.99] (0.98–0.99) 1DRs [0.99] (0.98–0.99) 2DRs [0.97] (0.99-0.99) Controls: 1DRs [0.99] (0.98–0.99) 2DRs [0.99] (0.99-0.99)
Soegaard100 2008 Denmark | Cases (n=579): female ovarian cancer probands recruited from gynecological departments; Controls (n=1,564): population based from civil registry | Index Test: Personal interview (1DR) Reference Standard: Cancer registry | Cases: [0.70] (0.54–0.86); κ=0.68 (0.55–0.82) Controls: [0.69] (0.59–0.80); κ=0.69 (0.60–0.78) | Cases: [0.99] (0.99–1.00) Controls: [1.00] (0.99–1.00)
Ziogas101 2003 U.S. | Probands with breast (n=670), ovarian (n=123) and colorectal (n=318 both male and female) cancer from clinic based family registries | Index Test: Telephone interview (1DR, 2DR, 3DR) followed by mailed GRIS pedigree Reference Standard: 1) Medical records or 2) Self-reporting from relatives or 3) Death certificates of deceased relatives | 174/194; [0.90] (0.84–0.93) | 1454/1498; [0.97] (0.96–0.98)
Colorectal Cancer in Relatives (Affected only)
King99 2002 U.S. | Probands with prostate cancer (n=143) from the cancer center | Index Test: Interview Reference Standard: Medical records and death certificates | Accuracy rates for colon cancer Documented (%) 88.9% Accurate (%) − 91.7%

Abbreviations: 1DR=first degree relative; 2DR=second degree relative; 3DR=third degree relative; BC=breast cancer;

CI=confidence interval; DARCC= Diet, Activity and Reproduction in Colon Cancer; FH=family history; GRIS=genetics registry system; HBOCS=hereditary breast-ovarian cancer syndrome; LFS=Li-Fraumeni Syndrome; n=number of subjects; NR=not reported

Table 7 Accuracy of self-reporting of FH for cancer in studies that verified the status for ovarian cancer in relatives

Study | Population/ Design/ Sample size | Index Test (FH) Reference Standard | Accuracy
| | | Sensitivity(95%) a/a+c; value[ ] | Specificity(95%) d/ b+d; value [ ]
Ovarian Cancer in Relatives (Affected and Unaffected)
Kerber95 1997 U.S. | Cases (n=125): colon cancer probands from DARCC study health administration database Controls (n=206): population based from DARCC health administration database | Index Test: Personal interview (1DR and 2DR) Reference Standard: Utah population health database; Cancer registry | Cases: 2/3; [0.67] (0.09–0.99) Controls: 1/5; [0.50] (CI NR) | Cases: 117/122; [0.96] (0.91–0.99) Controls: 201/204;[0.98] (CI NR)
Soegaard100 2008 Denmark | Cases (n=579): female ovarian cancer probands recruited from gynecological departments; Controls (n=1,564): population based from civil registry | Index Test: Personal interview (1DR) Reference Standard: Cancer registry | Cases: [0.44] (0.27–0.61); κ = 0.57 (0.40–0.73) Controls: [0.42] (0.25–.59); κ = 0.47 (0.31–0.63) | Cases: [1.00] (1.00-1.00) Controls: [1.00] (1.00-1.00)
Ziogas101 2003 U.S. | Probands with breast (n=670), ovarian (n=123) and colorectal (n=318 both male and female) cancer from clinic based family registries | Index Test: Telephone interview (1DR, 2DR, 3DR) followed by mailed GRIS pedigree Reference Standard: 1) Medical records or 2) Self-reporting from relatives or 3) Death certificates of deceased relatives | 35/42; [0.83] (0.69–0.93) | 1017/1028; [0.99] (0.98–0.99)
Ovarian Cancer in Relatives (Affected Only)
King99 2002 U.S. | Probands with prostate cancer (n=143) from the cancer center | Index Test: Interview Reference Standard: Medical records and death certificates | Accuracy rates for ovarian cancer: Documented (%); Accurate (%)− 100.0%; 50.0%

Abbreviations: 1DR=first degree relative; 2DR=second degree relative; 3DR=third degree relative; BC=breast cancer; CI=confidence interval; DARCC= Diet, Activity and Reproduction in Colon Cancer; FH=family history; GRIS=genetics registry system; HBOCS=hereditary breast-ovarian cancer syndrome; LFS=Li-Fraumeni Syndrome; n=number of subjects; NR=not reported

Table 8 Accuracy of self-reporting of FH for cancer in studies that verified the status for prostate cancer in relatives

Study | Population/Design/Sample size | Index Test (FH) Reference Standard | Accuracy
| | | Sensitivity(95%) a/a+c; value[ ] | Specificity(95%) d/ b+d; value [ ]
Prostate Cancer in Relatives (Affected and Unaffected)
Chang104 2006 Sweden | Cases (n=1,508): lymphoma cancer probands from cancer registries, hospitals, and clinics; Controls (n=1,229): randomly sampled from the population | Index Test: Telephone interview (1DR) Reference Standard: Cancer registry | In any 1DRs: Cases: [0.47] (0.44–0.49) Controls: [0.60] (0.57–0.63) | In any 1DRs: Cases: [0.99] (0.98–0.99) Controls: [0.99] (0.99–1.00)
Kerber95 1997 U.S. | Cases (n=125): colon cancer probands from DARCC study health administration database Controls (n=206): population based from DARCC health administration database | Index Test: Personal interview (1DR and 2DR) Reference Standard: Utah population health database; Cancer registry | Cases: 11/16; [0.69] (0.41–0.89) Controls: 21/30; [0.7] | Cases: 101/109; [0.93] (0.86–0.97) Controls 166/176; [0.94]
Ziogas101 2003 U.S. | Probands with breast (n=670), ovarian (n=123) and colorectal (n=318 both male and female) cancer from clinic based family registries. | Index Test: Telephone interview (1DR, 2DR, 3DR) followed by mailed GRIS pedigree Reference Standard: 1) Medical records or 2) Self-reporting from relatives or 3) Death certificates of deceased relatives | Cases: 46/58; [0.79] (0.67–089) | Cases: 557/564; [0.99] (0.98–0.99)
Prostate Cancer in Relatives (Affected only)
Zhu98 1999 U.S. | Cases: Probands (n=181) with prostate cancer Controls (n=297): enrolled in Group Health Cooperative | Index Test: Self-reporting data Reference Standard: Medical records, death certificate | Cancer in Brothers Cases 40–64y: κ = 0.85 (0.65–1.00) 65–69y: κ = 0.39 (0.14–0.65) Controls 40–64y: κ = 0.52 (0.16–0.88) 65–69y: κ = 0.60 (0.31–0.88) Cancer in Fathers Cases: 40–64y: κ = 0.76 (−0.55–0.98) 65–69y: κ = 0.70 (0.45–0.94) Controls:40–64y: κ = 0.24 (−0.15–0.62) 65–69y: κ = 0.51 (0.20–0.82)
King99 2002 U.S. | Probands with prostate cancer (n=143) from the cancer center | Index Test: Interview Reference Standard: Medical records and death certificates | Accuracy rates for prostate cancer: Documented (%); A ccurate (%)− 69.0%; 86.2%

Abbreviations: 1DR=first degree relative; 2DR=second degree relative; BC=breast cancer; CI=confidence interval; DARCC= Diet, Activity and Reproduction in Colon Cancer; FH=family history; GRIS=genetics registry system; HBOCS=hereditary breast-ovarian cancer syndrome; LFS=Li-Fraumeni Syndrome; n=number of subjects; NR=not reported; y=years

Table 9 Accuracy of self-reporting of FH for cancer in studies that verified the status for other cancers in relatives

Study | Population/ Design/ Sample size | Index Test (FH) Reference Standard | Accuracy
| | | Sensitivity(95%) a/a+c; value[ ] | Specificity(95%) d/ b+d; value [ ]
Other Cancer in Relatives (Affected and Unaffected)
Chang104 2006 Sweden | Cases (n=1,508): lymphoma cancer probands from cancer registries, hospitals, and clinics; Controls (n=1,229): randomly sampled from the population | Index Test: Telephone interview (1DR) Reference Standard: Cancer registry | Hematopoietic system cancer Cases: [0.60] (0.57–0.62) Controls: [0.38] (0.35–0.40) Any cancer in any 1DRs: Cases: [0.85] (0.83–0.87) Controls: [0.80] (0.83–0.87) | Hematopoietic system cancer Cases: [0.98] (0.97–0.99) Controls: [0.99] (0.98–0.99) Any cancer in any 1DRs Cases: [0.89] (0.87–0.91) Controls: [0.92] (0.90–0.94)
Mussio106 1998 Switzerland and Italy | Probands (n=193) with cancer (type not specified) recruited from two different sites from population-based cancer registries | Index Test: Standardized Questionnaire interview Reference Standard: 1) Medical records 2) Cancer registry | Mixed cancers by study group: Study A: [0.85] Study B: [0.74] Study A+B: [0.82] | Mixed Cancers by study group: Study A: [0.97] Study B: [0.97] Study A+B: [0.97]
Other Cancer in Relatives (Affected Relatives Only)
Aitken105 1996 Australia | Participants of the Queensland Familial Melanoma Project (913 cases) | Index Test: FH questionnaire Reference Standard: Medical records | Medical confirmation of melanoma as the diagnosis was obtained for 623/1040 (59.9%; 95% CI: 56.9–62.9%). A false positive reporting rate by cases of 40.1%
Novakovic103 1996 U.S. | Deceased relatives of probands (n=122) with Ewing’s sarcomas | Index Test: Questionnaire Reference Standard: Medical records and death certificates | % Agreement between self-reporting and death certificate 52% (63/122) dead relatives 1DR or proxy spouse: 58% 2DR: 48% % Disagreement between self-reporting and death certificate: 13% (16/122) dead relatives 1DR 12% 2DR 14

Abbreviations: 1DR=first degree relative; 2DR=second degree relative; FH=family history; cancer syndrome; n=number of subjects

In general, specificity across all cancer types and with varying modes of collection was consistently high (Tables 5 to 9). For reporting of breast cancer FH, specificities of 91 to 100 percent were reported; for colon cancer, 91 to 99 percent; for ovarian cancer, 96 to 100 percent; for prostate cancer, 93 to 99 percent. For lymphoma in relatives, rates were equally high. Two studies using population controls and samples from large registries100,104 showed that specificities were not altered by the type of cancer reported in relatives; sensitivities were higher for cancers at more common sites (for example breast and lung) and lower for less common sites (such as leukemia, and lymphoma). The sensitivity varied by the cancer of interest; for reporting of relatives with breast cancer, the range was 72 to 95 percent (Tables 5 to 9); for colon cancer, 33 to 90 percent; for ovarian cancer, 42 to 83 percent; and, for prostate cancer, 47 to 79 percent. From the limited data, it was not possible to draw definitive conclusions about the effects of either the method of collecting cancer FH, or the method of verification of relatives’ reported status, on sensitivity.

There were five case control studies95,97,98,100,104 that allowed direct comparison of reporting accuracy between affected and unaffected informants. In general, there were not significant differences between cases and controls with regards to specificity. However, controls reported lower sensitivities in lymphoma for 1DR with hematopoietic cancer,104 and ovarian cancers (sample size very low for this cancer).95 In contrast, higher sensitivities were reported in controls of relatives with colorectal cancer.95,97

Predictors of accuracy in cancer FH were not consistently evaluated across all the studies probing accuracy of self reported cancer FH. Factors related to informants that have been evaluated in eligible studies include age, gender, education level, and race, and marital status, type of cancer, setting, and insurance status. Factors associated with relatives include, degree of relation, type of 1DR, age, gender, cancer site/type, and time since diagnosis. We summarize the factors most frequently evaluated.

Eight studies91,95–97,100–102,104 evaluated the age of the informant as a predictor of accuracy with mixed results. Four studies showed that younger age (<50 and 50–59) was associated with higher specificity,104 or that accuracy increased overall with younger age95,100,101 while one96 showed decreased accuracy with younger age and three found no age effect.91,97,102 No clear trend emerges, and the type of cancer does not seem to be a factor. It was also difficult to compare across studies as the manner in which age intervals were categorized was not consistent.

Six studies95–97,101,102,104 examined an association between the informant’s gender and accuracy, and no general trend was observed. One study95 suggested higher accuracy in reporting relatives with ovarian cancer by women than men. Another study101 suggested lower specificity of reporting relatives’ cancers by men compared to women.

Six studies95–97,101,102,104 evaluated the effect of education level using a variety of categorizations; none showed any effect with the exception of two studies. These studies showed that for subjects with ovarian cancer and longer education (>10 years) had decreased sensitivities100 for reporting all types combined and breast cancer alone and those with college versus high school education had increased accuracy in subjects with breast cancer genetic syndromes.94

Four studies93,94,97,102 examined associations between accuracy and the degree of relative whose status was being reported. There was a consistent trend towards increased accuracy of reporting relating to 1DR compared to 2DRs or 3DRs. One study97 noted challenges in confirming the true status of 2DRs and that fewer 2DRs and 3DRs were identified overall, suggesting the potential for reporting and confirmation biases. Two studies100,104 showed that the type of 1DR (for example parent versus sibling) did not affect the high specificity rates and did not differ for controls or cases; the sensitivities were slightly lower for daughters and sisters of controls only.100

Quality and risk of bias in studies. Webfigure 1, Appendix C details the nine individual items used to evaluate risk of bias. We summarize the three primary flaws observed within this group of studies. The risk of spectrum bias was high, given that seven of the studies were case control in design (indicating the presence of spectrum bias as not representative of range of persons within primary care) and the remaining populations had cancer and were recruited from specialized settings. For example, one study92 involving informants affected by breast cancer was restricted to those aged under 40 years, one third of whom were affected by bilateral breast cancer, and were referred to a tertiary level oncology center. Although there are some challenges in characterizing the spectrum of patients with cancer, some studies included very high risk or atypical cancer patients, particularly for breast cancer, rather than patients with all levels of risk for cancer.

Partial or differential biases may lead to overestimation of accuracy.157 The disease status was verified in both affected and unaffected relatives in all but five studies91,94,99,102,105 suggesting that partial verification bias was limited. However, even in the studies that adequately attempted to evaluate the status of unaffected relatives, many subjects with incomplete data (due to linkage problems, or difficulty ascertaining confirmation) were excluded from the analyses. For some studies, up to 31 percent92 of relatives could not have their disease status verified. Another study103 showed that 11 percent of death certificates were inconclusive and that up to 24 percent of certificates for deceased relatives could not be located.103 Reported difficulties included, errors in medical records or pathology reports,92,103 death of relative prior to registry formation or other form of record keeping,92 emigration of relatives, incorrect addresses for relatives or contact information for hospitals, refusal of access to death certificate information or destruction of files,102 and inability to secure consent from the relatives in question.102

Blinding those verifying cancer status in relatives to the status of the informant was less of an issue in these cancer accuracy studies. For some studies the use of record linkage strategies was independent of the status of the relatives.100,104 Lack of blinding could lead to differential interpretation particularly where the information contained in medical charts is ambiguous. Bias due to lack of blinding might be less likely to have occurred in studies where verification was based on cancer or hospital registries, and where the diagnoses would have been checked through a separate process. However, there are other errors associated with linking databases that can lead to misclassification of disease status. Overall, blinding of data collectors to the status of the relative or the informant was not undertaken in the majority of studies, suggesting a high risk of masking bias.

Summary. There were 16 studies evaluating accuracy of reporting cancer FH. These studies recruited probands with breast cancer,91–94 colorectal cancer,95–97 prostate cancer,98,99 ovarian cancer,100 mixed cancers (breast, ovarian, colorectal),101,102 Ewing’s Sarcoma,103 lymphoma,104 melanoma,105 and unspecified cancer.106 Subjects were recruited predominately from specialized settings or cancer registries which would suggest a high risk of spectrum and selection bias.

The methods of cancer FH collection varied as did the questions or tools used to collect FH. Similarly, the methods used to verify relatives’ cancer status were primarily multimodal and relatives for whom verification could not be obtained were excluded from analyses.

Some studies examined only specific cancer family histories, while others examined all cancers of interest. Overall, specificity across all cancer types and with varying modes of collection was consistently high (>90 percent); sensitivities were lower and generally more variable (40 to 90 percent) depending on the cancer types. Two large studies using data linkages to registries100,104 showed that specificities were not altered by the type of cancer reported in relatives; that sensitivities were higher for cancers at more common sites and lower for less common sites. Five case control studies showed no significant differences between cases and controls with regards to specificity although controls reported lower sensitivities in lymphoma,104 and in colorectal cancer.95,97

Predictors of accuracy in cancer FH were not consistently evaluated across all studies. Factors that have been evaluated in eligible studies include informant age, gender, education level, and race, and marital status, type of cancer, setting, and insurance status. Factors associated with relatives include, degree of relation, type of 1DR, age, gender, cancer site/type, and time since diagnosis. No clear trend emerges with age, gender, or education level of the informants and the impact on accuracy. There was a consistent trend towards increased accuracy of reporting relating to 1DR compared to 2DRs or 3DRs.

Overall, these 16 studies are at high risk of spectrum and verification biases, which may cause an overestimation of accuracy (see Webfigure 1, Appendix C).

### Accuracy of Self-Report of Mental Health Disorder FH

There are unique challenges when evaluating accuracy of reporting FH in persons with mental illnesses. Traditionally, FH is sought from the proband or control subject (index test) and verification of the FH is sought by contact with the relative (reference standard). However, in mental health disorders this is not the typical approach for collecting or verifying FH, where informants (usually relatives) are sought to establish FH. In general, this raises the problem of disentangling accuracy of medical history versus accuracy of reporting FH as the index test.

Most mental health illnesses are diagnosed primarily using clinical criteria, necessitating confirmation of the presence of symptoms or behaviors in the individuals being assessed. In some situations where a genetic link is presumed, the diagnosis is substantiated by a positive FH (i.e., bipolar disorders). The person who is suspected to have the mental illness may not have sufficient insight into their condition to report the presence of these diagnostic symptoms; similarly, it is not clear if they can identify the presence of these symptoms in relatives. This is particularly the case when there is cognitive impairment (e.g., dementia) or the patient is in an acute phase of the mental health illness (e.g., manic phase of bipolar disorder). Informants who have health information about the proband, their relatives, or both are often sought as an adjunct to establishing a probable diagnosis. There is the added conundrum that if the relatives also have a mental illness, verification of their own or the probands’ disease status is potentially problematic, the relatives themselves may not be aware that they also may have a mental illness.

Figure 39 shows a schematic of the manner in which FH (index test) is collected in studies evaluating persons with mental health disorders. Scenario A represents the typical pathway to collect FH where persons who have the disease (probands) or who do not (controls) are queried directly about the disease status of their relatives. In this case the index test is based on information from the probands or control; in an ideal situation the proxy (who is usually a relative) is typically not included in the subsequent verification of the their own disease status (as a relative).

Figure 39 A schematic representation of collecting FH (Index test) in typical manner (A) and in persons with mental health disorders (B)(C)

Abbreviations: FH=family history; MH=medical history

Scenario B represents the standard approach in which FH (index test) is collected within families of probands with mental health disorders. The figure shows that the proband is very often not directly solicited for information about the disease status of relatives, but rather to indicate who might be a possible informant or relative to contact for further information. Scenario B represents the idealized situation where the informants provide assistance in establishing the presence of symptoms and behaviors (rather than presence or absence of disease) that would assist in “diagnosing” the mental health disorder in both the proband (medical history (MH)) and the relatives. Establishing a positive or negative FH is typically not determined by the informant; rather their report on the presence of symptoms is then used to establish a diagnosis for several mental health disorders. Note that scenario B assumes that the informant is different from the relatives. Scenario C represents the typical situation in mental health accuracy studies where relatives are informants with regards to their own disease status (or presence of key symptoms) and that of other relatives. Thus, the dilemma here is that informants, who are usually relatives, are present in both the index test (reporting symptoms or FH) and in verifying the disease status (reference test). The fundamental difference between the index and reference tests is the differing methods used to solicit information about the symptoms or disease status. Additionally, it is difficult to disentangle the “medical history” of the relative in the index test, versus the FH.

Essentially evaluation of accuracy in families with mental health disorders becomes a comparison of methods specific to accuracy of reporting of the informant, rather than the proband/proxy. As such, the accuracy within these studies represents the accuracy between two methods of collecting family and medical history from relatives or informants. Although the primary interest of this systematic review is on accuracy of reporting by the proband rather than the informant and on FH rather than medical history, we recognize that this may not be the norm within this clinical area. We alert the reader to this difference and where possible we attempt to present data that most likely reflects accuracy of FH rather than MH.

General study characteristics. Our systematic review identified 12 studies that evaluated the accuracy of collecting FH in persons with mental health disorders. One study collected FH but reported only on the accuracy of informant age of onset rather than accuracy of disease status in the relatives; as such, the results were not extracted for our research question.118

We grouped the remaining 11 studies based on the primary diagnosis of the probands; in the majority of studies, the subjects who were queried about FH were the relatives (predominately 1DR) of the probands. The disease outcomes for these studies were not restricted to those of the probands alone, but tended to include a variety of mental health disorders. Within studies evaluating mental health disorders, we include a series of studies with a mixed population of elderly with both dementia and depression.

There were three studies that evaluated relatives of persons with schizophrenia;107–109 three studies (four publications) that evaluated relatives of, or persons with, dementia and depression;110–113 and, four studies that evaluated relatives of persons with mixed disorders including depression and anxiety,114,115 personality disorders alone,117 and combined schizophrenia and bipolar affective disorders.116 We have grouped the presentation of the results according to these mental health disorder classifications.

### Schizophrenia and Related Disorders

Population. Three studies107–109 evaluated relatives (and some informants) of subjects with predominately schizophrenia related disorders. Although two of these studies108,109 included relatives of controls subjects, the results were not stratified by cases and controls; all three studies were therefore case series in design. The informants in each study were based on the FH reported by 1DRs although, with the exception of one study,107 the characteristics of these relatives were poorly described.

Method of FH collection in informants/probands. All three studies used a standardized instrument to collect FH (Family History Research Diagnostic Criteria, FH-RDC) and included additional standardized diagnostic questions specific to symptoms for schizophrenia and related subtype disorders (Table 10).

Table 10 Accuracy of self-reporting of FH for relatives with mental health illnesses

Study | Population/ Design/ Sample Size | Index Test (FH) Reference Standard | Accuracy
| | | Sensitivity(95%) a/a+c; value[ ] | Specificity(95%) d/ b+d; value [ ]
Schizophrenia in Relatives (Affected and Unaffected)
Fogelson108 2004 U.S. | Case series of probands (n=117) with adult onset schizophrenia recruited from inpatients public psychiatric hospitals and adult psychiatry outpatients. | Index Test: Structured FH (FH_RDC) Interview of at least two informants about 1DR Reference Standard: BED: Structured FH face to face interview (based on NIMH Relative Psychiatric History), plus DC (DIS, PSE) on 1DR, plus medical records (when available) | Schizophrenia: 2/8; [0.25] Any psychotic disorder: 8/18; [0.44] Schizoid personality disorder: 2/6; [0.33] | Schizophrenia: 246/247; [0.99] Any psychotic disorder: 237/237; [1.0] Schizoid personality disorder: 244/244; [1.0]
Li107 1997 U.S. | Case series of probands (n=48) with schizophrenia related disorders recruited from specialized schizophrenia center | Index Test: Structured FH (FH-RDC) and DC (SRD, SRP) telephone interview (1DR) Reference Standard: SFS method: Face to face interviews using the SADS and SIDP-R lifetime version on 1DR. Diagnosis made by consensus | Psychotic SRD:13/18 [0.72] Chronic Schizophrenia: 9/13; [0.69] Psychotic SRD and SRP: 31/56; [0.55] | Psychotic SRD:18/18; [1.0] Chronic Schizophrenia: 182/183; [0.99] Psychotic SRD and SRP: 129/140; [0.92]
Roy109 1996 Ireland | Case series of probands (n=402) with schizophrenia, or major affective disorder recruited from rural registry Controls (n=150) recruited from county electoral registry. IDR were the focus of this study | Index Test: Structured FH (FH-RDC) from >1 informant about 1DR Reference Standard: BED: Structured interview (SSPD, DSM-III-R), medical records, and FH information (two diagnosticians made final diagnosis) | Schizophrenia: [0.68] Schizoaffective disorder: [0.23] Bipolar disorder: [0.25] Unipolar depression: [0.26] | Schizophrenia: [0.994] Schizoaffective disorder: [0.997] Bipolar disorder: [0.993] Unipolar depression: [0.958]
Depression and Dementia in Relatives (Affected and Unaffected)
Heun112 1996 Germany | Case series of probands >60 years with depression or Alzheimer’s Dementia (n=100) Controls (n=40) from general population. | Index Test: Interviews FH (FH-RDC) plus DC (Dementia Risk Questionnaire, Dementia Questionnaire) Reference Standard: Interviews that included: CIDI, MMSE, and SIDAM) | Dementia: 5/24; [0.208] Depressive disorders: 12/30; [0.400] Anxiety disorders: 3/45; [0.067] Any psychiatric disorders: All relatives: 31/100; [0.310] Probands relatives: 28/74; [0.378] Controls Relatives: 3/26; [0.115] | Dementia: 263/266; [0.989] Depressive disorders: 250/260; [0.962] Anxiety disorders: 243/245; [0.992] Any psychiatric disorders: All relatives: 179/190; [0.942] Probands Relatives: 118/127 [0.929] Controls Relatives: 61/63; [0.968]
Heun111 1998 1998 110 Germany | Case series with probands >60 years of age with DAT and geriatric depression (n=75) | Index Test: Interview using the FH-RDC and DC (Dementia Risk questionnaire and Dementia Questionnaire) Reference Standard: Face to face interviews with DC (CIDI, SIDAM) | Diagnosis of dementia by FH information: Index subjects as informants: 23/28; [0.82] Relatives of pts and controls: 5/22; [0.23] p<0.001(t-test; d.f.=247) Diagnosis of depression by FH information: Index subjects as informants: 12/26; [0.46] Relatives of pts and controls: 5/12; [0.42] | Diagnosis of dementia by FH information: Index subjects as informants: 43/47; [0.92] Relatives of pts and controls: 167/173; [0.97] Diagnosis of depression by FH information: Index subjects as informants: 36/49; [0.74] Relatives of pts and controls: 177/183; [0.97] p<0.001(t-test; d.f.=247)
Mixed Mental Health Disorders in Relatives (Affected and Unaffected)
Lish115 1995 U.S. | Informants (n=77) and relatives (n=239) selected from participants in regional survey, or from specialty university clinics for persons with anxiety and depression | Index Test: FH Screen for Epidemiologic Studies (FHE) – interview of history and pedigree collection Reference Standard: BED: Direct interview using the SADS-lifetime anxiety version for adults or the K-SADS-E for children | Informants reporting on: selves; adult relatives; minors Major depression/ dysthymia: [0.674]; [0.352]; [0.000] Any affective disorder: [0.674]; [0.364]; [0.000] Any anxiety disorder: [0.905]; [0.522]; [0.000] Any FHE diagnosis: [0.887]; [0.622]; [0.364] | Informants reporting on: selves; adult relatives; minors Major depression/ dysthymia: [0.750]; [0.849]; [0.973] Any affective disorder: [0.750]; [0.848]; [0.973] Any anxiety disorder: [0.686]; [0.818]; [0.918] Any FHE diagnosis: [0.733]; [0.718]; [0.735]
Rougemont- Buecking116 2008 Switzerland | Case series evaluating informants (n=1,625) and index subject pairs (siblings, parents, an adult offspring, or spouse). Probands (n=621) included both inpatients and outpatients with psychiatric disorders. Controls (n=105) from an orthopaedic ward were also recruited | Index Test: Structured personal interview using the FH- RDC and DC (1DR and spouses) Reference Standard: Interview-derived diagnoses using the DC that included the DIGS, GAD, SAD-LA, OCD. | Any anxiety disorder: [0.185] Panic disorder: [0.136] Social phobia: [0.119] GAD: [0.111] OCD: [0.059] | Any anxiety disorder: [0.948] Panic disorder: [0.991] Social phobia: [0.981] GAD: [0.974] OCD: [0.992]
Weissman114 2000 U.S. | Case series with probands and informants with childhood diagnosis of depression (n=199) or anxiety (n=65) Healthy controls (n=175); from these a total of 289 were included in this study | Index Test: Brief FH screen (1DR) Reference Standard: BED based on independent and blind direct interviews using the SAD-LA | Proband reports on Relatives Any diagnosis [52.5] (SE 3.8) Any depression [37.9] (SE 4.6) Major depression [37.9] (SE 5.4) Any anxiety [23.6] (SE 5.4) | Proband reports on Relatives Any diagnosis [68.0] (SE 4.5) Any depression [85.1] (SE 2.8) Major depression [81.2] (SE 2.8) Any anxiety [89.2] (SE 2.2)
Ferro117 1997 U.S. | Case series with probands (n=224) with a variety of personality disorders; 1DR relatives were also interviewed. | Index Test: FH interview for personality disorders (FHIPD) (IDR) Reference Standard: Structured interview using the PDE, SCID-NP, and the EPQ | Concordance measured by kappa between PDE and FHIPD, by disorder: Paranoid: 0.10 Schizoid: 0.19 Schizotypal: −0.01 Antisocial: 0.28 Borderline: 0.15 Histrionic: 0.04 Narcissistic: 0.07 Avoidant: 0.21 Dependent: 0.05 Obsessive-compulsive: 0.11 Passive-aggressive: 0.10 Self-defeating: 0.04

Abbreviations: 1DR=first degree relative; BED=best estimate diagnosis; CIDI=Composite International Diagnostic Interview; DAT=Dementia of the Alzheimer type; DC=diagnostic criteria; DIGS=diagnostic interview for genetic studies; DIS=diagnostic interview schedule; DSM=Diagnostic and Statistical Manual; Dx=diagnosis; EPQ=Eysenck personality questionnaire; FH=family history; FHE=family history for epidemiologic studies; FHIPD=family history interview for personality disorders; FH-RDC=family history research diagnostic criteria; GAD=general anxiety disorder; K-SADS-E=Schedule for affective disorders and Schizophrenia suitable for children and adolescents - episode; MMSE=Mini-mental state examination; n=number of subjects; NIMH=National Institute of Mental Health; OCD=Obsessive compulsive disorder; PD=Parkinson’s disease; PDE=personality disorder examination; pts=patients; PSE=present state exam; SAD-LA=Schedule for affective disorders and Schizophrenia lifetime anxiety version; SADS=Schedule of affective disorders and Schizophrenia; SCID-NP=Structured clinical interview, non–patient version; SE=standard error; SIDAM=structured interview for the diagnosis of Dementia of the Alzheimer type, Multi-infarct Dementia and Dementias of other etiology; SRD=Schizophrenia related disorder; SRP=Schizophrenia related personality disorder

^ =for controls

Method of verification in informants/relatives. All three studies used multiple strategies (termed best estimate diagnosis (BED)) that included direct interview (including FH and diagnostic criteria), medical records when available, and diagnosis by one or more expert clinicians.

Study outcomes. All studies evaluated FH for schizophrenia and related subtype disorders; one study109 included history of bipolar related disorders and additional categories such as alcohol abuse. Table 10 details the accuracy outcomes for these studies; the presentation of results is limited to those of primary schizophrenia and bipolar disorders (accuracy outcomes for all subtypes is not shown). Overall, these three studies show consistently high specificity and poorer sensitivity. The sensitivity rates for schizophrenia were moderate (72 to 68 percent) in two studies,107,109 but very low in another study (25 percent).108 Related subtypes of schizophrenia, for example schizoaffective or atypical psychosis, had lower sensitivities (varying from 0 to 55 percent across studies); this suggests that the diagnostic subtype may be a factor affecting the estimates of sensitivity. The sensitivity estimate for bipolar disorders was low (25 percent) compared to schizophrenia (68 percent) in the same study.109

One study109 evaluated factors likely to affect the false positive rate, including subject (person for whom disease status was given), and attributes such as, previous hospitalization, female gender, and older age. For the informant (person who reported FH) the diagnosis of an affective disorder increased false positives. These findings suggest that difficulties in informant perceptions of psychiatric behaviors account for the inaccuracies. Another study107 found no significant association between the type of 1DR and estimates of accuracy.

Quality and risk of bias in studies. All three studies were at high risk for spectrum bias, as the informants were predominately relatives of the probands who were recruited from specialized clinics. In all studies, it was difficult to ascertain which relatives (or informants) refused or were unable to participate in the study, suggesting high risk of selection bias. With the exception of one study,109 there was also a high risk of partial verification bias as it was not clear why some informants did not receive the reference standard test. Similarly, no attempts were made to seek verification of disease status in relatives who were deceased or who could not participate in direct interview.107–109 In two studies107,108 it is likely that FH collection (index test) may have been included in the BED (reporting unclear) suggesting the potential for incorporation bias. Only one study stated explicitly that the diagnosticians were masked to both the status of the relative and the proband prior to undertaking the reference test.109 However, masking to the proband status is likely to have minimal impact given that the informants were the subjects of these studies.

Summary. Three case series studies107–109 evaluated relatives of subjects with predominately schizophrenia related disorders and bipolar disorder.109 The majority of the sample of informants was 1DRs of the probands, with some inclusion of control relatives; however, results were not stratified for cases and controls. All studies used a standardized test (FH-RDC) to collect FH from informants and similarly used standardized psychiatric diagnostic tests to establish disease within the relatives. Overall, these three studies show consistently high specificity and poorer sensitivity; sensitivity varied with the diagnostic subgrouping. The single study109 that evaluated schizophrenia and bipolar disorders showed lower sensitivities for the later diagnostic group. All three studies were at high risk for selection and verification biases likely leading to overestimation of accuracy.

### Dementia and Depression

Population. Four case series studies110–113 by the same primary author evaluated geriatric subjects with dementia and depression. One of these studies110 collected FH of 1DRs and their spouses and combined information in the context of informant pairs (eliminating true familial relationship); as such the results of this study do not reflect accuracy of true FH and the data are not presented here. The studies evaluated relatives of patients with Alzheimer’s dementia, major depression, or both disorders; one study111 included data from the probands’ accuracy of medical history as well. Controls subjects and their relatives were recruited in all three studies from the general population; the proportion of these varied with each study and not all results were stratified for this group. The informants in all studies were predominately 1DRs, but small numbers of spouses, 2DRs, and other relatives were also included. The method of recruiting the relatives was not well described and information on those relatives refusing participation was not reported.

Method of FH collection in informants/probands. FH was collected in all studies using the FH-RDC instrument and included the use of other diagnostic screening instruments (see Table 10).

Method of disease verification in informants/relatives. Status of the index subjects was determined using standardized psychiatric instruments to diagnose dementia and depression.

Study outcomes. The studies evaluating this geriatric group showed that probands/controls and informants (predominately 1DR) are more accurate in identifying which relatives do not have dementia and depression (specificity range from 74 to 99 percent). All studies showed a difference in sensitivities for diagnosing dementia (21 to 23 percent) compared to depression (34 to 46 percent) (Table 10); sensitivity of anxiety disorders was lowest across all studies (7 or 8 percent).

One study111 estimated accuracy of probands and controls using two different forms of interview with the reference standard being the psychiatric criteria interview; similarly, they probed relatives using these two different methods. Their findings suggest that probands/controls have higher sensitivity in reporting dementia FH (82 percent) than do their relatives (23 percent); this difference did not hold for diagnosing depression in family members (sensitivity 46 versus 42 percent). It is difficult to interpret these findings given that so little information other than age and gender was provided about probands and controls; it is not clear how the cognitive status of the probands may have influenced these results. Two studies112,113 showed some differences in sensitivity for relatives of probands (38 percent) compared to relatives of controls (12 versus 16 percent) when diagnosing any psychiatric disorder; specificities were higher (93 to 97 percent) and did not differ markedly for this psychiatric outcome.

Quality and risk of bias in studies. All the studies evaluating relatives and probands with dementia and depression were at high risk of spectrum and selection bias; no information about relatives that did not participate was provided. A single study111 was not found to be at risk for either type of verification bias (partial or differential) or masking bias. The timing of the index and reference standard tests was not clearly specified in any study. Given the limited number of studies, there is a high risk for bias leading to overestimation of accuracy within this group of studies.

Summary. Four case series studies110–113 by the same primary author evaluated geriatric subjects with dementia, major depression, or both; one study presented informant pair data not consistent with FH accuracy and was not extracted.110 All studies used a standardized test (FH-RDC) to collect FH in informants and similarly used standardized diagnostic psychiatric tests to establish disease within the relatives. All studies within this patient group would suggest that probands and informants are better at identifying relatives that do not have depression or dementia. However, these studies are at high risk of bias, and the results should be interpreted with caution.

### Other Disorders of Mental Health

Population.There were four additional studies that collected FH from populations with affective or anxiety and depression disorders,114,115 personality disorders,117 and persons with bipolar affective disorder, major depression, schizoaffective substance abuse, and substance addictions.116 This later study was grouped within the category of mixed disorders rather than schizophrenia, as these represented a very small proportion of subjects and the outcome of this study was any anxiety disorder. All studies were case series in design; however, three studies included healthy subjects and their relatives.114,116,117 At least two informants were sought per index subjects in most studies.114,116,117 In general, it was difficult to disentangle which of the informants were relatives (sharing genetic material) and which were not.

Method of FH collection in informants/probands. FH was collected in all studies using standardized instruments (Table 10).

Method of disease verification in informants/relatives. In all studies, confirmation of disease status was obtained using BED by independent clinicians.

Study outcomes.Table 10 shows the specific disease outcomes. We have reported those with the highest specificity or frequency of diagnoses. The presentation of results in these studies is confounded by the use of informant pairs, which may include information from or about spouses of probands or spouses of their relatives.

A single study117 evaluated the degree of agreement (kappa) between the proband self-reporting versus their relative’s direct reports; this study showed very low agreement (ranging from −0.1 to 0.21) suggesting that probands and relatives provide different perspectives on the presence of a variety of personality disorders. Another study114 showed widely varying estimates of sensitivity (from 23.6 to 52.5 percent) depending on the type of anxiety disorder; specificity varied from 68 to 89.2 percent. Accuracy of both proband self-reporting and relative self-reporting for mental disorders showed higher sensitivities and lower specificities overall; no consistent effect of age and gender or type of relative on accuracy was found.

Similar results were shown in a study that evaluated anxiety disorders in probands with predominately affective disorders; low sensitivities (6 to 19 percent) and higher specificities (97 to 99 percent) were observed.116 This study also showed some effects of female index subject on accuracy for some anxiety disorders, suggesting some over-reporting and lower accuracy overall. A final study115 showed lower sensitivities and higher specificities when reporting FH of anxiety disorders; however the magnitude of the estimates for anxiety disorder sensitivities were almost triple those reported in another study.116 The authors conclude that the FH tool used is not adequate for specialty settings, but suggest that it may be appropriate as a screen in primary care settings.115

Quality and risk of bias in studies. Webfigure 2, Appendix C details QUADAS ratings for these studies. All the studies had high risk of spectrum bias, as the subjects would not be typical within a primary care setting. As with most studies in the mental health area, it is difficult to determine which of the relatives did not have their disease status verified suggesting high risk of bias for both partial and differential verification. Masking of the clinicians who determined the BED was not an issue in these studies.

Summary. There were four additional studies that collected FH from populations with affective or anxiety and depression disorders,114,115 personality disorders,117 and persons with bipolar, major depression, schizoaffective substance abuse, and substance addictions.116 FH was collected in a structured and standardized manner; BED was used in all studies to determine the status of the relatives. In general, probands and relatives were more accurate in reporting who did not have affective or anxiety related disorders; sensitivities for major depression and any psychiatric disorder were higher than those for anxiety disorders and levels of agreement were very low for personality disorders. As a group, these studies represent a broad group of mental health illnesses, and still show a consistent trend with respect to accuracy. However, all these studies are at high risk for spectrum and differential biases.

### Accuracy of Self-reporting of Parkinson’s Disease FH

Population. Two studies evaluated incident cases of Parkinson’s disease120 from a population-based sample, and cases from a Parkinson and movement disorder clinic.119 One was a true case control study120 and the other, which did not stratify by proband disease status,119 is classified as a case series. Controls were recruited from communities and matched for demographic factors such as age, gender, or ethnicity.119,120 Parkinson’s disease in probands was determined using the Unified Parkinson’s Disease Rating scale and the Mini Mental Health Status (MMSE) in one study119 and established clinical diagnostic questions in the other study.120 One study120 did provide some information on the median duration of Parkinson’s Disease, (mean 8 years with a range from 0 to 24 years) while the other did not specify the characteristics of cases.119

Both studies allowed for proxy informants when cases or controls were deceased or unable to complete the interview. One study119 detailed the proxy participants and showed that only 36 percent of cases (50 percent for controls) were able to directly respond to the interview. The proxy respondents included predominately offspring (cases 58 percent, controls 49 percent) and spouses (nieces/stepchildren, relatives-in-law) (cases 33 percent, controls 22 percent).

Method of FH collection in informants. FH reported by the informants was captured using a standardized single question120 or series of questions that assisted in establishing the presence of symptoms used to diagnose Parkinson’s disease (Table 11).119 Both studies included questions about the composition of families.

Table 11 Accuracy of self-reporting of FH for relatives with other diseases

Study | Population/Design/Sample Size | Index Test (FH) Reference Standard | Accuracy
| | | Sensitivity(95%) a/a+c; value[ ] | Specificity(95%) d/b+d; value [ ]
Parkinson’s in Relatives (Affected and Unaffected)
Elbaz120 2003 U.S. | 1) Cases: probands (n=133) with Parkinson’s disease accrued from medical records-linkage system of state county. 2) Controls (n=119): from local community 3) Proxy informants were primarily 1DR for deceased and incapacitated subjects | Index Test: Standardized FH (and DC) telephone interview Reference Standard: Structured FH (and DC) telephone interview of 1DR followed by clinical examination (positive screen only) | Cases: 17/25; [0.68] (0.47–0.85) Controls: 05/11; [0.45] (0.17–0.77) | Cases: 622/630; [0.99] (0.98–0.99) Controls: 499/500; [1.0] (0.99–1.0)
Marder119 2003 U.S. | 1) Cases: probands (n=304) with non-demented PD recruited from specialized centre 2) Community controls (n=232) 3) Proxy Informants (for 1DR who could not be interviewed or were deceased) | Index Test: Personal or telephone interview (1DR) Algorithm to assign level of certainty to the diagnosis Reference Standard: 1) Telephone interview with relatives followed by neurological examination 2) Medical record review (for deceased relatives) | By certainty of PD diagnosis (Dx): Liberal Dx: 22/22; [1.0] Conservative Dx: 21/22; [0.955] Definite or probable Dx: 16/22; [0.727] Definite Dx: 12/22; [0.545] | By certainty of PD diagnosis (Dx): Liberal Dx: 98/104; [0.942] Conservative Dx: 100/104; [0.962] Definite or probable Dx: 103/104; [0.99] Definite Dx: 103/104; [0.99]
Diabetes in Relatives (Affected and Unaffected)
Bensen124 1999 U.S. | Sample from the NHLBI Family Heart Study (n=3020) selected randomly and non-randomly (oversampled with CHD). Some of the probands had CHD, diabetes, hypertension, and asthma | Index Test: Mailed questionnaire including personal history and FH (1DR and spouses) Reference Standard: Same questionnaire as probands | Diabetes Proband vs Parent 0.87 (p=0.032) κ=0.83 Proband vs Sibling 0.72 (p=0.021) κ=0.72 | Diabetes Proband vs Parent 0.98 (p=0.005) κ=0.83 Proband vs Sibling 0.98 (p=0.002) κ=0.72
Murabito123 2004 U.S. | Participants from Framingham Offspring study (males = 791, females 837) Some probands had high blood pressure, diabetes, high cholesterol, heart attack <55 yrs, and stroke < 65 yrs. | Index Test: Structured questionnaire including personal history and FH (1DR father and mother separately) Reference Standard: Research database (original Framingham cohort) that contained medical records of both parents | Diabetes Within Fathers 56 (50–62) Within Mothers 65 (59–71) | Diabetes Within Fathers 97 (96–98) Within Mothers 97 (96–98)
Bochud121 2004 Switzerland | Case series of families selected from an ongoing national register of hypertension (n=384) and diabetes (n=404) who attended primary health care centers | Index Test: Structured questionnaire including personal history and FH (1DR) Reference Standard: Clinical assessment | Diabetes Sibling report of history: [0.534] (0.433–0.633) Clinical status: [0.614] (0.501–0.719) | Diabetes Sibling report of history: [0.982] (0.971–0.989) Clinical status: [0.978] (0.966–0.986)
Karter122 1999 U.S. | Subgroup of African American (and non-Hispanic) participants (n=206) from population (n=43,533) survey study; probands had diabetes and one additional relative affected | Index Test: Telephone interview – FH questionnaire (1DR, 2DR) Reference Standard: Telephone interview with relative to complete pedigree | Overall concordance [κ]: Diabetes in paternal grandfathers: =0.76 Diabetes in mother: =0.90
Hypertension, Stroke, and Cardiovascular Disease in Relatives (Affected and Unaffected)
Bochud121 2004 Switzerland | Case series of families selected from an ongoing national register of hypertension (n=384) and diabetes (n=404) who attended primary health care centers | Index Test: Structured questionnaire including personal history and FH (1DR) Reference Standard: Clinical assessment | Hypertension Sibling report of history: [0.89] (0.864–0.913) Clinical Status: [0.898] (0.866–0.924) | Hypertension Sibling report of history: [0.776] (0.732–0.816) Clinical Status: [0.554] (0.514– 0.595)
Murabito123 2004 U.S. | Participants from Framingham Offspring study (males=791, females 837) Some probands had high blood pressure, diabetes, high cholesterol, heart attack <55 yrs, and stroke <65 yrs | Index Test: Structured questionnaire including personal history and FH (1DR father and mother separately) Reference Standard: Research database (original Framingham cohort) that contained medical records of both parents | Hypertension Within Fathers [0.44] (41–47) Within Mothers [0.57] (54–60) High Cholesterol Within Fathers [0.19] (17–21) Within Mothers [0.18] (16–20) | Hypertension Within Fathers [0.88] (86–90) Within Mothers [0.90] (88–92) High Cholesterol Within Fathers [0.92] (90–94) Within Mothers [0.95] (93–97)
Bensen124 1999 U.S. | Sample from the NHLBI Family Heart Study (n=3020) selected randomly and non-randomly (oversampled with CHD). Some of the probands had CHD, diabetes, hypertension, and asthma | Index Test: Mailed questionnaire including personal history and FH (1DR and spouses) Reference Standard: Same questionnaire as probands | Hypertension Proband vs Parent 0.76 (p=0.021) κ=0.58 Proband vs Sibling 0.56 (p=0.013) κ=0.47 | Hypertension Proband vs Parent 0.84 (p=0.018) κ=0.58 Proband vs Sibling 0.91 (p=0.006) κ=0.47
France126 1998 U.S. | Undergraduate student volunteers (age 19 to 50 y) (n=493) participated in a health survey | Index Test: FH questionnaire on parental blood pressure information (1DR) Reference Standard: FH questionnaires on blood pressure mailed to biological parents; telephone interview | Hypertension Maternal history: [0.604] Paternal history: [0.737] Both parents combined: [0.682] | Hypertension Maternal history: [0.963] Paternal history: [0.890] Both parents combined: [0.929]
Murabito123 2004 U.S. | Participants from Framingham Offspring study (males = 791, females 837) Some probands had high blood pressure, diabetes, high cholesterol, heart attack <55 yrs, and stroke <65 yrs. | Index Test: Structured questionnaire including personal history and FH (1DR father and mother separately) Reference Standard: Research database (original Framingham cohort) that contained medical records of both parents | Heart Attack <55 yr Within Fathers 74 (64–84) Within Mothers Too few events Death by heart disease Within Fathers 81 (77–85) Within Mothers 72 (65–79) Stroke <65 yr Within Fathers 42 (32–52) Within Mothers 51 (40–62) | Heart Attack <55 yr Within Fathers 91 (90–92) Within Mothers Too few events Death by heart disease Within Fathers 86 (84–88) Within Mothers 91 (90–92) Stroke <65 yr Within Fathers 96 (95–97) Within Mothers 98 (97–99)
Silberberg128 1998 Australia | Cases: patients (n=432) with CHD enrolled in population study that registered all suspected of coronary event Controls (n=248) population controls from the same region | Index Test: Modified FH questionnaire from literature Reference Standard: Death certificates | CJD reported for 1DRs Cases: CHD: [0.85] (0.74–0.92) All heart disease: [0.83] (0.75–0.90) Controls: CHD: [0.95] (0.84–0.99) All heart disease: [0.90] (0.80–0.96) Reported for 2DRs Cases: CHD: [0.80] (0.71–0.87) All heart disease: [0.76] (0.69–0.82) Controls: CHD: [0.80] (0.72–0.86) All heart disease: [0.76] (0.70–0.81) | CHD reported for 1DRs Cases: CHD: [0.59] (0.49–0.69) All heart disease: [0.70] (0.58–0.80) Controls: CHD: [0.74] (0.65–0.82) All heart disease: [0.83] (0.73–0.90) Reported for 2DRs Cases: CHD: [0.68] (0.61–0.75) All heart disease: [0.80] (0.72–0.86) Controls: CHD: [0.65] (0.60–0.71) All heart disease: [0.74] (0.67–0.80)
Bensen124 1999 U.S. | Sample from the NHLBI Family Heart Study (n=3020) selected randomly and non-randomly (oversampled with CHD). Some of the probands had CHD, diabetes, hypertension, and asthma | Index Test: Mailed questionnaire including personal history and FH (1DR and spouses) Reference Standard: Same questionnaire as probands | CHD Proband vs Parent 0.85 (p=0.023) κ=0.76 Proband vs Sibling 0.81 (p=0.015) κ=0.80 | CHD Proband vs Parent 0.93 (p=0.010) κ=0.76 Proband vs Sibling 0.98 (p=0.002) κ=0.80
Klungel125 1999 The Netherlands | Probands with hypertension (n=899) subjects from a cross-sectional population-based study (n=36,000) | Index Test: Self reported information on cardiovascular diseases with question on FH Reference Standard: Medial records | Overall concordance [κ] (95% CI): MI in father: [0.07] (0.04–0.10) MI in mother: [0.05] (0.02–0.07)

Abbreviations: 1DR=first degree relative; 2DR=second degree relative; CHD=coronary heart disease; CI=confidence interval; DC=detailed family composition; Dx=diagnosis; FH=family history; MI=myocardial infarction; n=number of subjects; PD=Parkinson’s Disease; y=years

Method of verification in relatives. Both studies119,120 evaluated Parkinson’s Disease in 1DRs and screened for the presence of disease with diagnostic questions; subsequent to this, relatives that screened positive were invited for neurological examinations or, in the case of deceased relatives, medical records were reviewed. One study119 also compared informant and relative’s self-reporting (stratified by 1DR sibling, parents, or offspring); only a small subgroup of relatives was subsequently selected for verification by neurologist examination and review of medical records. Evaluation in both affected and unaffected relatives was intended in both these studies.

Study outcomes and direction of findings.One study, 119 evaluated the accuracy of 1DRs based on methods of diagnosis that varied from liberal (for example, a single symptom), to definite diagnosis (that included presence of several symptoms and confirmation from a specialist). This same study reported the percent agreement between the informants and relatives self-reporting as a function of the diagnostic criteria. The findings showed lower kappa values for liberal diagnosis criteria (0.41, 95 percent CI 0.23–0.59) than for definite diagnostic criteria (0.80, 95 percent CI 0.53–1.00) for any 1DR relative. A similar trend was reported for siblings of the informants. The ranges of degree of agreement were different when offspring were probed, with kappa varying from 0.69 (95 percent CI 0.48–0.89) for definite diagnosis to 0.74 (95 percent CI 0.63–0.85) for liberal criteria. Within this same study, a smaller subsample was selected and verification of disease status in the relatives showed that informants (either cases or controls) were more accurate in identifying relatives who did not have Parkinson’s disease.119 The sensitivity markedly declined as the certainty of disease improved. Although we note that this subgroup of informants and their relatives where characterized by fewer controls, the findings would suggest neither the gender of the informant nor whether they were cases or controls affected this trend. Overall, parents of the informants had better sensitivities than siblings or offspring.

A second study120 also showed that informants were more accurate in reporting relatives who did not have disease (Table 11). This trend was not different for cases or controls; controls had the lowest sensitivity (45 percent controls versus 68 percent in cases). Nor was this trend affected by the type of interview (proxy or direct), characteristics of the relative (parents or sibling), or the life status (deceased or not). The study findings would suggest that offspring (in comparison to siblings or parents) had lower sensitivities (60 versus 100 percent) and specificities (98 versus 99 percent).

Quality of studies. Several areas of potential biases were noted within these two studies. Three biases, selection, verification, and masking, were judged most likely to affect study outcomes and are summarized here; all relevant QUADAS items are detailed in Webfigure 3, Appendix C.

As both studies were case control in original design, they are prone to selection bias (QUADAS item 1). In addition, one study119 did not specify how a subsample, chosen for purposes of validation, was selected and showed unequal number of controls (only 20 controls and 76 cases). Both studies attempted to evaluate affected and unaffected relatives and as such, risk of partial verification bias was low (QUADAS item 5). Both studies used multiple methods to verify the disease status of the relatives (for example, self-reporting of relative and neurologist examination) and these were clearly described. However, both studies were prone to differential verification bias, as confirmation of deceased or incapacitated relatives’ necessitated different reference standard methods (QUADAS item 6). In addition, both studies asked additional questions for those who responded positively to either the presence of Parkinson’s Disease120 or to those who had at least one Parkinson’s symptom; informants and relatives who responded no or who had no positive symptoms were assumed to be disease free.

The risk of biasing due to lack of blinding during interpretation of the index or reference tests was not consistent across studies. Although a high proportion of proxy informants (63 percent were 1DR) were used in one study, these 1DRs were excluded from further data collection;120 the second study did not clarify any exclusions due to participation as proxy informant (QUADAS item 10).119 The data collectors were not blinded for all methods used to verify the status of the relative in either study (QUADAS item 11).

Summary. Two studies evaluated accuracy of reporting in persons with Parkinson’s disease.119,120 Both studies used multimodal strategies for establishing disease status within the 1DRs. One population-based study showed that informants were more accurate at identifying relatives without the disease (specificity); this study also showed that cases were more accurate than controls (68 percent versus 45 percent) in correctly identifying relatives with Parkinson’s disease (sensitivity).120 A second study119 also showed that informants were more accurate at identifying relatives without Parkinson’s disease for the diagnostic certainty categories of “definite/ probable” and “definite”. Their findings suggest that the degree of certainty of diagnosing Parkinson’s disease, impacts the level of agreement between informants and relatives self-reporting of disease status. This trend in accuracy was not affected by the type of interview, type of 1DR, or the life status of the relative.

Given that there is risk of bias in more than one area within so few studies, we judge that there is high risk of bias affecting the interpretation of the results, likely causing an overestimation of accuracy.

### Accuracy of Self-reporting of Diabetes FH

Population. Four studies evaluated the accuracy of reporting FH of diabetes on subjects with diabetes,122 and hypertension or diabetes121 and from cohorts with mixed diseases.123,124 The study designs used included case series,121 cross-sectional,122 and longitudinal cohorts.123,124

Method of FH collection in informants/probands. Face to face interview121 telephone interview122 and self-administered questionnaire123,124 were used to capture FH (Table 11).

Method of disease verification in informants/relatives. Disease status of the relatives was verified with clinical assessment,121 and interview or questionnaire.121–124

Study outcomes and direction of findings. One study124 showed differences in sensitivities for parents (87 percent) versus siblings (72 percent); specificities (98 percent) were not altered by type of 1DR. Another study123 compared accuracy for reporting for mothers and fathers and showed slightly higher sensitivities for mothers (56 versus 65 percent); there were no differences in specificities (97 percent) (Table 11). Another study121 showed high specificity (98 percent) with lower sensitivity (53 to 61 percent ) for both methods of verification (either interview with the sibling or with clinical data). One study122 reported only concordance values varying by paternal grandparents (kappa=0.76) and mother (kappa=0.90).

Quality and risk of bias in studies. Webfigure 4, Appendix C shows the QUADAS rating for these studies. All studies included subjects with the disease, but two studies123,124 selected subjects that were representative of primary care and therefore less prone to spectrum bias. Only one study121 was at risk for differential verification bias as not all records or death certificates were found for all potential subjects. Masking bias was difficult to assess in most studies for the reference standard.

Summary. Four studies evaluated the accuracy of reporting FH of diabetes in subjects with diabetes,122 hypertension or diabetes,121 and from cohorts with mixed diseases.123,124 FH was captured in a standardized manner and verification included contact with relatives, self-administered questionnaire, or clinical assessment. Overall, specificities ranged from 97 to 98 percent and sensitivities varied from 53 to 87 percent. When reporting FH of diabetes, subjects are more accurate at identifying relatives that do not have the disease. Quality of these four studies would suggest that the risk of bias was low.

### Accuracy of Self-reporting of Cardiovascular Diseases FH

Population. Six studies evaluate d healthy students,126 subjects with hypertension,125 hypertension or diabetes,121 definite or probable myocardial infarction (MI),128 and two studies evaluated probands from longitudinal study cohorts with and without a variety of diseases including stroke, hypertension, MI and diabetes. Three studies were case series in design,121,125,126 two were longitudinal designs,123,124 and one case control.128

Method of FH collection in informants/probands. A variety of methods were used to capture FH (Table 11) but all were well described and standardized.

Method of disease verification in informants/relatives. Disease status was verified with medical records,123,125 death records,128 clinical assessment,121,123 records from research database,123 and interview or questionnaire involving relatives.121,124,126

Study outcomes and direction of findings. Hypertension: Four studies reported on hypertension within relatives; from these, two studies123,126 showed sensitivities (0.57–0.60 percent) and specificities (0.90–0.96 percent) for reporting of disease in mothers was higher than those for fathers (sensitivity 0.44–0.74, specificity 0.88–0.89 percent). In contrast another study126 in undergraduate volunteers showed that reporting paternal hypertension was more sensitive (74 percent) than for maternal disease (60 percent), but specificities were still high (89 to 96 percent) (Table 11). Another study124 compared accuracy of reporting of hypertension in parents and siblings, and showed lower sensitivities (56 versus 76 percent) but higher specificities (84 versus 91) for siblings. A single study121 showed the opposite trend with higher sensitivities (90 percent) and lower specificities (55 to 78 percent).

Heart disease:Four studies evaluated accuracy of reporting cardiovascular disease 123,124,128 MI,123,125 and stroke.123 One study125 evaluating concordance with reporting MI, showed better agreement for fathers than mothers (Table 11). Another study123 showed accuracy of reporting of disease in mothers relative to fathers (Table 11); generally specificities (91 to 98 percent) were higher than sensitivities. Sensitivities were lowest for stroke (42 to 51 percent) and highest for death by heart disease (72 to 81 percent) with variable differences in parental gender due to the disease endpoint. A similar trend with higher specificity was shown in another study124 and no appreciable differences were observed when reporting on disease in parents or in siblings. In contrast, a case control study128 showed higher sensitivities (83 to 95 percent) for both cardiac heart disease and all heart disease for both cases and controls; specificities ranged from 59 to 83 percent.

Other factors affecting accuracy: One study evaluated the impact of differing positive family history definitions with broad classification (for example heart attack at any age) or narrower parameters (for example, heart attack <55 years).123 This study showed that broader definitions of FH increased true positives, and positive predictive values and sensitivities.

Three studies evaluated the impact of proband characteristics, and mixed results were shown. One study123 showed age of the proband did not impact accuracy. Another study124 showed that older adults (55 or older) had a greater probability of disagreement, however this varied with the four diseases evaluated. Similarly, there were some variations for the type of relative; for example older probands with cardiovascular disease had greater probability of disagreement with reporting disease in siblings and spouses than in parents. Across all diseases evaluated, no clear trend emerges.

Comparison of cases and controls within one study128 showed higher sensitivities (85 and 90 percent) for 1DRs; 1DRs of controls tended to have the highest sensitivities (90 and 95 percent). For 2DR relatives, the pattern between sensitivities (76 to 80 percent) and specificities (65 to 80 percent) was less pronounced. In another study probands with disease reported less accurately for all relatives and for all disease types except cardiovascular disease.124

In two other studies the presence of a risk factor for a disease123 or having the disease128 did not affect estimates of accuracy relative to those that were free of the disease or risk factor.

Quality and risk of bias in studies. Webfigure 5, Appendix C shows the QUADAS rating for these studies. Three of the studies123,124,128 had large population based samples representative of primary care. Relative to these studies, those with smaller sample sizes studies were prone to differential bias. It was difficult to assess the risk of masking bias for the reference standard in most studies. Criteria for subject selection and withdrawals were well described in most studies.

Summary. Six studies evaluated accuracy of reporting hypertension,123–125 hypertension or diabetes,121 definite or probable MI,123,128 and stroke123 in their relatives, predominately 1DR. FH was captured in a standardized manner for all studies and verification included contact with relative (interview or postal questionnaire), or death certificate or medical record. All but one study128 reporting sensitivity and specificity generally showed lower sensitivities across hypertension and other cardiovascular outcomes.

## Question 3. What is the Direct Evidence That Routinely Getting a Family History Will Improve Health Outcomes for the Patient and/or Family?

### General Approach

We selected studies that identified the impact on health related outcomes of systematic collection of FH in a typical, non-selected primary care/general population.

Appropriate health related outcomes identified from studies included patients’ screening intention,158 uptake of and adherence to screening tests and procedures,136,158–166 preventative health behavior,129,130,162 and prophylactic preventive treatment and surgery.167

Our focus was on the systematic collection of [underlined: individual] FH information, and communication of [underlined: personal] risk of one or more of the conditions of interest, in populations considered representative of primary care populations. In line with the decision to identify the highest level of evidence, only published intervention studies (RCTs, controlled trials, and uncontrolled before-after studies), where the intervention was the systematic collection of FH and this was compared to current or control clinical practice, were included for this question. Webtable 30 identifies those studies excluded, primarily because the design was not the specified intervention study design.

### Studies Reviewed

Only two studies were identified for data abstraction after full text review of 34 studies.129,130 Both were uncontrolled before-after studies and focused on breast cancer risk assessment, including FH collection, as the target intervention.

The employer study focused on telephone based risk assessment (including systematic FH collections) in female patients at their place of work. In the study,129 all 8,900 women employees were sent electronic mail and there was a poster campaign about the breast cancer telephone risk assessment service. Five percent (444) took up the service and 343 completed the telephone survey, with 189 agreeing to divulge their names and addresses, enabling followup. These 189 subjects were sent a followup postal questionnaire at 8 months, achieving a response rate of 72 percent (136). The baseline telephone survey and followup postal survey enquired about the outcome measure of mammography, as well as reporting clinical breast exam (CBE) and breast self exam (BSE).

In the other study130 participants were recruited, on a walk-in basis, through six community pharmacies and two health promotion events for women aged 18 years or older. Prior to intervention, respondents completed a baseline survey (as indicated in Table 12). The risk factor data (including FH) was input into a breast cancer risk assessment tool. This tool used the Gail model for risk calculation, which requires information on the number of 1DRs with breast cancer. This was followed by a pharmacist consultation to discuss individual breast cancer risk, supplemented by written information. All women, irrespective of risk status, were encouraged by the pharmacist to follow American Cancer Society (ACS) guidelines for BSE, CBE and mammography. As with the employer study, the baseline and followup surveys enquired about adherence to mammography, (together with adherence to CBE and BSE).

Table 12 Description of studies with evidence that routinely getting a FH will improve health outcomes for the patient and/or family

Author Year Design Setting | Target Behavior | Population n Followup | FH Collection Component of Intervention | Who Delivered Intervention | Outcome Measures | Findings
Kadison129 1998 Before-after Two large employers, Boston, MA, U.S. | Screening mammo BSE Clinical breast exam | Female employees invited by electronic mail n=343 recruited n=136 followup at 8 months | Telephone-administered survey for 12 Risk factors. 1. Number of 1DRs with breast cancer (inc. age of diagnosis); Relatives with bilateral breast cancer. 2. Other risk factors: age at menarche, pregnancy history, age and weight at menopause; history of ovarian/uterine cancer; chest radiotherapy | Automated telephone based Breast Cancer Risk Assessment System: real time risk information and option of paper copy of risk assessment and advice | Compl with monthly BSE, CBE by a healthcare practitioner and mammo | Proportions comply with screening BSE Pre: 40/119 Post: 74/119 p<0.001 CBE Pre: 98/119 Post: 110/119 p<0.0137 Mammo Pre: 22/29 Post: 27/29 (in 6 months following assessment) p<0.0572
Giles130 2001 Before-after Community pharmacies and health screening event, Richmond, VA, U.S. | Screening mammo BSE Clinical breast exam | Women ≥ 18y invited by a walkup basis n=188 recruited n=140 followup at 6 months | Interviewer-administered survey: 1. Number of 1DRs with breast cancer 2. Other risk factors: age at menarche, age at first live birth, number of breast biopsies 3. Other: history of practicing BSE, formal instruction in BSE, confidence in performing BSE, history of mammography | Community Pharmacist | Adherence with ACS guidelines for BSE, CBE, and mammo | Proportions following ACS guidelines (self-reporting) (% (95% CI*) BSE Pre: 42/137 (31 (23–38)) Post: 77/137 (56 (48–64)) p<0.001 CBE Pre: 121/140 (86 (81–92)) Post: 128/140 (91 (87–96)) p<0.09 Mammo ≥50y Pre: 33/44 (75 (62–88)) Post: 31/44 (70 (57–84)) p<0.48 40–49y Pre: 18/32 (56 (39–73)) Post: 21/32 (66 (49–82)) p<0.257

Abbreviations: 1DR=first degree relative; ACS=American Cancer Society; BSE=breast self exam; CBE=clinical breast exam; Compl=Compliance; FH=family; Mammo=Mammography; n=number of subjects; y=years

### Outcomes

The study findings are summarized in Table 12. In the employer study, based on 12 risk factors (including FH) women were classified as being at low to average, moderately increased, or markedly increased breast cancer risk. All women were advised to perform CBE and regular BSE and mammography.

The original cohort of 343 women had a similar age range to the general U.S. population but a higher proportion reported recent mammography. Further, a high proportion of the 343 women initially recruited had a FH of breast cancer with 10 percent (34) having a 1DR diagnosed with breast cancer before the age of 50. Of the 136 women who completed both telephone survey and followup postal survey, 52 percent (70) reported changing breast screening behavior. There was a statistically significant improvement in the two risk reducing behaviors: Mammography screening improved from 76 to 93 percent but the matched sample was small (29) and the change in screening did not reach statistical significance (p=0.057). There was also improvement in BSE (34 to 62 percent; P<0.001) and CBE (82 to 92 percent: p<0.0137). There was no differentiation of the improvement in breast screening habits between the different risk strata.

The community pharmacy study drew participants from women attending pharmacies and heart health events, and no specific data were presented regarding representativeness. Their analyses indicate that 21 of 140 (15 percent) participants were assigned to the high risk category (≥1.7 percent risk of breast cancer in 5 years), which appears higher than would be expected for an unselected female population in this age group. In addition, the high baseline rates of mammography and CBE compared with published figures for the general population may indicate that this study has limited external validity.

There was limited improvement in adherence to mammography in all women (p=0.796) and each age group (40–49; >= 50 years old). Further, in high breast cancer risk women (with relative risk >=1.7) the adherence fell from 81 percent (17/21) to 71 percent (15/21), although this did not reach statistical significance (p<0.317). Results were also presented for other process measures: the proportion of women performing BSE increased from 31 to 56 percent, while mean BSE performed over 6 months increased from 2.79 to 4.1. Both metrics identified statistically significant changes (p<0.001). Changes in CBE were less dramatic with an increase from 86 to 91 percent (p<0.09). However, in younger women (aged 40–49) the change was slightly more significant with improvement in CBE from 81 to 99 percent (p<0.025).

### Quality Assessment of Studies

In the before and after employer study there appears to be selection bias, with recruited participants being younger and having higher breast cancer risk than the U.S. general population, and with higher proportions reporting recent mammography. If it is assumed that the 4 percent (343) of invited patients who participated and completed the baseline survey were more health conscious, then there is also a potential for recall bias. Over the 8 months of the study response rate fell from 77 percent of the 444 participating women completing the baseline telephone survey, to 31 percent (136) at followup. The telephone-based breast risk assessment intervention took place at the same time as a Breast Cancer Awareness Month at one employer, making it difficult to determine whether the improvement in breast screening behavior was a direct consequence of the telephone-based service.

The community pharmacy study was described as a ‘randomized, paired, pre-post study’, which is misleading. In our assessment, it was an uncontrolled pre-post study in which before-after outcomes for individual participants were analyzed as paired data. No control group was used and therefore no random allocation was possible. The potential for bias in this study is high, given that no assessment could be made of the influence of external factors, or placebo or Hawthorne effects. The study indicated an a priori sample size calculation; their assumptions about baseline adherence rates may have been erroneous, as they were unusually high at around 70–80 percent for CBE and mammography (also suggesting a possible ceiling effect).

### Conclusion

The evidence base for addressing Q3 is limited to two studies. This was primarily due to restrictions on study design but also, clearly defining the population as representative of primary care excluded the numerous studies in a specialist setting. In both studies, familial breast cancer risk was not considered in isolation but as part of a multifactorial risk assessment tool. It was not possible to disentangle the impact of the FH risk assessment from the other risk factors. In both studies, the interventions did not really resemble the routine, personal interaction, which might occur between a primary care professional and an individual patient. In the employer study, risk assessment was offered to all women employees of two large U.S. organizations. It might be expected that such a recruitment procedure would be representative of the general population, however, the recruited patients were more representative of a high risk population (including high familial risk). Similarly, the recruited patients were different from the general population in other ways: baseline mammography screening levels and the matched data indicated the population already had a high BSE rate. The external validity of the results was also affected by non-response to followup survey and, as acknowledged by authors, the study was underpowered for some of the outcome measures. The low participation rate (5 percent) is a weakness of the study, but it probably represents a realistic situation when an open invitation for risk assessment is offered to the general uninformed population. Both uptake of this service and followup screening would be improved if recommended by the woman’s usual physician. In the community pharmacy study, the subjects were recruited through a local screening campaign, and no data was available on the representativeness of the recruited women. Like the employer study, the proportion of women at high breast cancer risk and the baseline screening behavior was higher than expected for an unselected U.S. population. As well as concerns about the external validity of both studies, they were only able to assess process measures (mammography screening; BSE; CBE), with mammography screening being the only outcome with evidence of improved health outcomes. In both studies, there was limited improvement in mammography screening however, the sample sizes were small. Further, in the community pharmacy study subanalyses suggested those identified at high breast cancer risk adhered less to mammography, however this change was not statistically significant, with high baseline screening rates.

## Question 4. What is the Direct Evidence That Routinely Getting a Family History Will Result in Adverse Outcomes for the Patient and/or Family?

### General Approach

We reviewed published studies, which assessed negative impacts of systematically collecting FH information and providing patients with familial risk information for any medical condition. The focus was on systematic collection of [underlined: individual] FH information, and communication of [underlined: personal] risk of one or more of the conditions of interest, in populations considered representative of primary care populations.

The adverse psychological outcomes of interest identified at full text review included perceived risk,158,160,162,166,168,169 and perceived vulnerability and worry.131–133,158,162,168

In line with our decision to identify the highest level of evidence, only published intervention studies (RCTs, controlled trials, and before-after studies), where intervention was the systematic collection of FH and this was compared to current or control clinical practice, were included for this question. Webtable 30 identifies those studies excluded, primarily because they were not the required intervention study design.

### Studies Reviewed

After reviewing 38 studies at full text, only three studies met all eligibility criteria.131–133 These studies recruited patients from single British primary care offices with the number of respondents recruited varying from 100 to 666 and response rates of 19, 29, and 64 percent. Descriptions of each study are given in Table 13. A sample size calculation was provided in one of the studies.133 The proportion of recruited patients completing survey items at all time points was 91, 89, and 76 percent respectively.131–133

Table 13 Description of studies with evidence that routinely getting a FH will result in adverse outcomes for the patient and/or family

Author Year Setting Design | Disease | Population n | Time Points for Analysis | Duration/Nature of Interventio n | Who delivered Interventio n | Method of FH Collection | Other Intervention
Leggatt1 31 2000 U.K. Before -After ucon study | Colorectal/colon/rectal Breast cancer | Unselected patients aged 35 to 65 years registered at one general practice Recruited= 666 (29% response) Completed =604 | Baseline 1–1.5 months | N/A Postal FH question | Lower risk group: letter from family doctor Potential increased risk groups: family doctor and/or Oncologist/geneticist | Postal cancer FH question | Participants provided with risk information
Qureshi1 33 2001 U.K. RCT | Generic covered all conditions identified by respondent | Random selection of patients aged 18–60 registered at one general practice for at least 2 years, and who had not received a health check in that time Recruited= 100 (64% response) Completed =76 | Baseline 1 week 2 weeks 3 months | Two consults, two weeks apart (completing FH question and health check in 1^st^ consult) | FH screening question intervention only: self-admin, results reviewed by a clinical geneticist Health Check (control + intervention ): Researcher results reviewed by a GP | In-office self-admin FH question with prompt sheet of relevant conditions
Rose132 1999 U.K. Before and After uncon study | Generic covered all conditions identified by respondent | Unselected patients aged 20–34 years registered at one general practice, excluding pregnant women Recruited= 124 (18.9% response) Completed =91 | Baseline Immed post-consult 12 weeks | 30 minute genetic consult (taking a 3 generation FH and completion of question) | GP and health visitor. the latter had previously worked as a clinical nurse specialist in genetics | Recorded on a pro forma during clinic appt | Participants provided with lessons on pregnancy planning, lifestyle factors, and general information regarding familial risk

Abbreviations: FH=family history; FHQ=family history questionnaire; GP=general practitioner; Immed=Immediate; N/A=not applicable; question=questionnaire; RCT=randomized controlled trial; ucon study=uncontrolled study

One paper133 described a randomized controlled trial (RCT) comparing general anxiety, health status and specific FH measures between control patients receiving a general health check and intervention patients who completed a FH risk assessment with the health check. Outcomes were measured using the self-administered short form (six items) Spielberger State-Trait Inventory (STAI) and the five item Perception of Health Questionnaire at baseline, 1 week, 2 weeks and 3 months after first visit. The 12-item FH concerns measure (adopted from self-administered Psychological Consequences Questionnaire) was also completed at 2 weeks and 3 months. The health check comprised two visits: baseline to record standard health check variables and, in the intervention arm, the self-completed FH questionnaire. Two weeks later the results of the health check and FH questionnaire were reported back to the patient, including recommended action. The 2 week outcome survey was completed immediately after this consultation.

The two other studies131,132 were both uncontrolled before-after studies with different interventions. One131 evaluated the psychological impact of collecting cancer FH information through a postal questionnaire distributed to all patients in the 35 to 65 age group, followed by individualized assessment of their genetic risk of CRC and breast cancer (where appropriate). General anxiety and cancer worry were assessed at baseline and 4 to 6 weeks after risk information feedback using the STAI and a multidimensional cancer worry scale, respectively.

The other study132 assessed the impact of offering a familial risk assessment and counseling clinic to identify genetic and preconceptual issues in patients of child-bearing age (20 to 34). As well as identifying the uptake and acceptability of the clinic, general anxiety was assessed immediately before and after the clinic appointment and 12 weeks later with the short form STAI.

### Outcomes

In the first study133 156 patients were randomly assigned to control and intervention groups, with 100 patients attending doctor’s office for routine physical examination. Seventy-six completed outcome surveys at all 4 time points. In the intervention group, mean STAI score at baseline was 36.7, rising to 39.4 at 1 week and falling back to 37.1 at 2 weeks; in the control group STAI mean score was similar at baseline but fell at 1 and 2 weeks (to 32.5 and 33.0 respectively). This corresponded to a significantly higher anxiety score for the intervention group at 1 and 2 weeks post clinic visit (p=0.014). The mean scores for the intervention and control groups at 3 months were not significantly different (34.2 and 34.8 respectively). When comparing perception of health scores at different time points, the only significant change between the groups was that a larger proportion of the FH intervention group gave a more pessimistic response between baseline and 1 week post-visit to questions about risk to future health, compared to the control group (26 vs. 7 percent; p=0.025). There was no significant difference between the two groups regarding FH concerns at 2 weeks and 3 months.

The second study131 analyzed participants in two groups. Lower risk’ (those at no more than slightly elevated risk) participants, for whom no followup was necessary, were given feedback by letter only. The outcomes for this group are summarized in Table 14. The STAI at baseline and 4–6 week followup were similar (35.8 and 35.1 respectively), corresponding to no statistically significant difference observed in anxiety. Similarly, most other cancer worry measures identified no statistically significant change following the intervention, with the exception of a small reduction in participants’ perception of their own risk (p<0.01).

Table 14 Findings from studies with evidence that routinely getting a FH will result in adverse outcomes for the patient and/or family

Author | Measure(s) | Description of Subjects Analyzed | Subjects | Main Findings | Other Findings
Leggett131 2000 U.K. | Anxiety Cancer worry scales - perceived own risk of developing cancer -freq. of cancer related thoughts - effect performance daily tasks - effect on mood | “Lower risk” Group | n=568 | No significant change between baseline and followup for both measures | Also no significant change between baseline and followup in other risk groups
Qureshi133 2001 U.K. | Spielberg State-Trait Anxiety Inventory (STAI) – short form Perception of Health Psychological Consequences Questionnaire (FH Concern) | All enrolled patients aged 18–60 years in single primary care office completing questionnaires at all 4 time points. | Complete data at all 4 time points Control: n=42 Intervention: n=34 | State Anxiety score (at weeks 1 and 2) higher in the intervention group than control (p=0.014), but did not persist (no significant difference at 3 months) | Perception of health measure: significant result at week 1, the intervention group having a more pessimistic response to the question eliciting pts concerns about future health (p=0.025) FH concern measure: no significant difference at 2 weeks or 3 months
Rose132 1999 U.K. | Spielberg State-Trait Anxiety Inventory (STAI) – short form | All enrolled patients aged 20–34 years in single primary care office | Complete baseline STAI: 121 +12 weeks: n=91 | State Anxiety score fell immediately after the consultation (p<0.001) and rose to pre-clinic levels at 12 weeks | Main lessons learnt by pts during consultation related to pregnancy planning and life-style advice, as well as genetics related topics

Abbreviations: FH=family history; Freq=frequency; n=number of subjects; p=probability; pts=patients

Of the remaining participants, most were interviewed to clarify details of their FH, which led to further designation into ‘higher risk’ and ‘false positive’ groups, the latter comprising patients deemed not actually to be at high risk after further enquiry. For both ‘higher risk’ and ‘false positive’ groups, no difference between baseline and followup responses to general anxiety and cancer worries scales was observed. However, both of these groups showed higher baseline cancer risk perception scores compared to the lower risk group (p<0.001 for ‘higher risk’ group and p=0.003 for ‘false positive’ group).

In the third study132 124 patients attended the primary care office-based genetic clinic, with 121 completing the pre- and post-clinic STAI and 91 returning the 12^th^ week. Eighty-nine patients completed the survey at all 3 time points. Fifty-four percent (67/124) of patients attended clinic due to concerns about possible familial illness, and 35 percent (43) attended for pregnancy planning. In the clinic, a three generation FH was recorded using a standard proforma and risk was assessed by primary care providers (family doctor and health visitor) against regional guidelines, literature, and standard texts. Forty percent (50) of patients had a FH with a genetic component, however only 7 percent (9) required specialist input. Based on all the completed surveys at each time point, the mean STAI score at baseline was 34.8, falling significantly to 30.1 (p<0.001) right after the consultation, returning to initial levels after 12 weeks (33.0). As commented by the authors, a significant proportion of the genetic counseling involved reassuring patients that they were at “low” familial risk. In the study publication, there was no differentiation of anxiety scores between the different risk strata.

### Quality Assessment of Studies

Two of the eligible studies were uncontrolled before-after studies,131,132 while the third study was a RCT.133 All took place in single primary care offices.

A standardized quality assessment checklist was employed on the study that used a randomized trial design.133 The modified Jadad scores were 5 out of 8 for this study. Although the randomization procedure was described in the paper, the allocation procedure was not clear. Similarly, criteria for participant inclusion were given, but no exclusion criteria were described. A sample size calculation was reported for the primary outcome measure. Identifying adverse events of the intervention was not scored but the objective of the study was to identify such factors. Further, the study did not report measures to achieve blinding.

No formal quality assessment checklists were employed on the two uncontrolled before-after studies.131,132 Neither study compared respondents and non-respondents to the familial risk assessment invitation. However, both did attempt to elicit profiles of non-responders in other ways. In one study, respondents were compared to the overall practice population, identifying that more older subjects took up the offer.131 The other study noted 81 percent of invited subjects did not respond, and a fifth (n=144) of these non-responders were sent a postal survey. One hundred and ten subjects replied with nearly 50 percent stating their reason for non-attendance was inconvenient time or lack of time, while another 40 percent were not motivated or considered assessment irrelevant to them. Nether study reported sample size calculations.

### Conclusion

The evidence base for addressing Q4 is limited to three studies, a randomized controlled trial133 and two uncontrolled before after studies.131,132 These suggest that structured FH collection and feedback of familial risk information had no deleterious psychological effects in the medium term (6–12 weeks) on patients who took up the FH intervention. Leggatt further identified the relationship between breast cancer familial risk status and psychological impact. There was no deleterious psychological effect in any of the risk groups, while in women who were at or just above average risk, the FH risk assessment may have led to appropriate reductions in perceived risk.

The most common psychological measure in all three studies was the short form of the STAI. However, the clinical significance of the score remains unclear. The baseline scores in the FH intervention arms did vary between the three studies from 34.8^132^ to 36.7.^133^ The three studies showed different short term impacts of intervention, in one study,133 there was a short tem rise in anxiety score while in the second,132 the score fell and in the third131 there was no change. Other than Leggatt,131 the studies did not differentiate the anxiety scores between lower and higher risk groups. In this study, there was no change in the anxiety and cancer worry in both risk groups at 4 and 6 weeks after cancer FH assessment. However, the finding of higher baseline levels of these psychological measures in the groups who went on to have further assessment is difficult to explain and may reflect the effects of having a positive FH in itself, rather than having FH information collected and assessed. Of the three studies only Leggatt et al.,131 used a validated context-specific measure (cancer worry scale). In another study a context-specific measure was adopted from a validated instrument (PCQ) but it did not demonstrate any significant impact of the FH collection intervention.133

## Question 5. What are the Factors That Encourage or Discourage Obtaining and Using a Family History?

### General Approach

Initially there was limited clarity on the breadth and depth of this research question. After extensive review of the diverse literature in this area and a series of discussions with the technical expert panel, we focused the reviewed publications on studies that clearly identified the association between factors that facilitate or inhibit the process of collecting, discussing, and/or using FH. Within the group of studies collecting FH, studies evaluating the association between self reported FH and other factors were separately collated. The process of FH collection, discussion and use can be influenced by attributes of the patient, the health care professional, and the setting in which the FH is identified. In line with the overall scope and purpose of the review, the patients were from populations representative of a primary care setting, while the practitioners would have been primary care providers (as discussed in Chapter 2).

### Studies Reviewed

Of the six studies identified, four were undertaken in primary care offices134–137 and in the another two studies the population was derived from patients being screened in the general population.138,139

Four studies were cross-sectional.135,136,138,139 The remaining two studies were a direct observational study137 and a prospective cohort study with a baseline cross-sectional survey.134 Factors associated with FH collection or discussion were the primary outcomes of interest of three studies.136,137,139 This relevant data from the other three studies were retrieved from subanalyses presented in these publications.134,135,138 Two studies only recruited female patients.136,138

The cross-sectional surveys recruited between 500 and 149,332 subjects. The direct observational study followed 4454 patient visits and the cohort study surveyed 163 patients.

In Murff et al.,136 patients with at least one visit to the primary care provider over the previous year were randomly selected from 11 primary care practice sites in the Greater Boston area. As well as medical record review, the consenting patients completed a telephone survey. This survey identified sociodemographic factors and satisfaction with health care. Only 2,858 women were included in the sampling frame for the study. The average age of the women was 47.6. The response rate was 62 percent (1,803) with responders more likely to have had a mammogram performed in the last 5 years. Fletcher et al.,135 also randomly mailed questionnaires to 6,807 of 31,959 patients aged 35 to 55 years old in a single large multispecialty group practice about FH of colorectal cancer and screening experience. Twenty-eight per cent (1,854) of this sample completed the postal survey, with 19 percent (355) of these respondents reporting a FH of colorectal cancer.

In Karliner et al.,138 the sample was derived from 14,490 women in the San Francisco area who had had a mammographic screening in the previous 2 years and completed a baseline questionnaire at the time of screening. The questionnaire identified women’s familial risk using the Gail model. In the sampling frame, women were randomly sampled according to risk status (although all higher risk minority women were included). Of 2,715 women in the sampling frame, 63 percent (1,700) completed a followup telephone survey. The telephone survey collected information on sociodemographic data, as well as, information on breast cancer risk and screening behavior. Pinsky et al.,139 also sampled from a large cross-sectional survey of the general population aged 55 to 74 years. The publication reports on the 149,332 subjects who completed the FH section of the baseline survey in a national multi-cancer screening trial. The expected prevalence rates of various cancer types were compared to observed levels for different relatives and gender of respondents. Further, the relationship with various socio-demographic factors was also identified.

In Acheson et al.,137 researchers directly observed consultations of 138 community family physicians over 2 separate days (4 months apart), with a standardized consultation encounter tool (modified Davis Observation Code). The study was restricted to family physicians practicing in North East Ohio, although the profile of the physicians was representative of physicians throughout the U.S. The observation was supplemented by a review of medical records, physician surveys, and field notes. Full details of the FH information was only extracted from medical records in the latter half of the study.

The study by Volk et al.,134 also recruited from a single primary care office in Boston. Among 1,098 subjects contacted by mail, 17 percent (189) consented to participate in the study, with 15 percent (163) completing a postal survey that incorporated a structured format to obtain FH information. As well as the survey, consenting subjects agreed to have their electronic medical records scrutinized for FH information and compared to the information collected on the survey.

### Outcomes

In the six studies, the FH outcome was predominantly a dichotomized variable. The outcomes of interest were: FH documented in medical records;134,136 FH discussed by doctor, either confirmed by direct observation137 or patient survey;135,138 and self reported FH.139,170 The study findings are summarized in Table 15.

Table 15 Factors associated with improved FH collection and utilization

| Factors Associated With Improved FH Collection in Medical Records | Factors Associated With Medical Practitioner Discussing FH | Factors Associated With Improved Self-reporting of FH
Patient factors: | White (compared to other ethnic groups)136 Certain medical conditions (diabetes, breast cancer, coronary artery disease)134 | Not on state health insurance137 Patients who worry about breast cancer138 Age: mixed picture, in one study more likely to discuss in younger age group for all conditions,137 while in another study in older age group for colorectal cancer135 | Women139 White non-Hispanics (compared to other ethnic groups)139 Higher education status139 Certain common cancers: breast, lung, and colorectal139
Practitioner factors: | | Practitioners in same practice for fewer years137 Resident-trained137
Setting: | | Routine physical examination in established patients,137 particularly women137,138

Abbreviations: FH=family history

FH recorded in medical records. Murff et al.,136 noted a comprehensive cancer FH risk assessment was more likely to be documented in white patients’ medical records (84 percent versus 67 percent in non whites), and in patients where English was the first language (94 percent English versus 85 percent), both with p<0.001. When dichotomized by age (less than 40 or 40 years and older) the ethnic difference remained. In the under 40 group, FH of breast cancer interviews occurred in 30 percent of white women, compared to 15 percent of African Americans and 11 percent of Hispanics (p<0.001). No information was presented on provider factors (practitioner and setting).

Volk et al.,136 identified a different factor in FH collection, the type of conditions identified in electronic health records (EHR) in U.S. primary care practice. Forty-seven percent of EHRs had a FH recorded (93/189). Compared to the postal FH survey, the EHR collected FH of diabetes, breast cancer, CHD, but 90 percent of positive family histories of glaucoma, osteoporosis, and colon cancer were better identified by systematic FH surveys. Compared to EHRs, the survey also identified further FH details on glaucoma, osteoporosis, and diabetes leading to alteration in their familial risk status (94.7, 95.0, and 73.8 percent of positive family histories, respectively, changed risk status).

FH discussed in consultation. Acheson137 identified the FH information discussed in consultations. FH was discussed in 24 percent of consultations. This study differentiated between factors that influenced discussion of FH between newly registered patients at the doctors’ office and established patients. Recently appointed physicians (as indicated by being in practice for fewer years) were more likely to discuss FH with established patients (p=0.02). In addition, 25 percent of residency trained practitioners discussed FH with established patients compared to 70 percent of non-residency trained practitioners (p=0.06). There was no association with practitioners who offered prenatal care.

In the case of patient factors: the age, gender, health and marital status were explored for established and new patients. The only significant association was that older established patients were less likely to discuss FH than younger established patients (age 15 to 44, 24.8 percent; 65 years or over, 17.6 percent; p<0.001) Further, patients with Medicare insurance were less likely to be asked about FH.

Family history was discussed in 61 percent of physical examinations with new patients, compared to 44 percent of such checks in established patients. During these checks, female patients were more likely to discuss FH. When FH was discussed this seemed to extend the consultation time and be associated with other problem being addressed in the consultation in both new and established patients.

Kartliner et al.,138 surveyed women who had attended mammography screening. The study explored multiple factors associated with clinicians discussing cancer FH. Jewish ancestry, education, language of interview, insurance status, previous cancer investigations, and worry or risk perception were not associated with clinicians discussing cancer FH. However there was an association with younger women (p<0.0001), women who had had a routine physical examination in the last year (p=0.0001), and women concerned about breast cancer (p=0.006). In Fletcher et al.,135 women younger than 50 were less likely to be asked about their FH of colon or rectal cancer with 39.1 percent asked [95 percent CI: 36.1–42.0%] compared to 72.2 percent asked in those 50 years and older [95 percent CI: 70.0–76.4%].

Factors associated with self-reporting FH. Pinsky et al.,139 noted in a cross-sectional survey that male respondents reported less FH of cancer than female respondents. The most common family histories reported were breast (11.8 percent), lung (10.1 percent), colorectal (9.4 percent), and prostate cancer (7.3 percent), with lymphoma (0.6 percent), vaginal (0.1 percent) and testicular cancer (0.4 percent) being less commonly reported. Further, it appeared liver and bone cancers were over-reported while lymphoma, melanoma, bladder cancer, and testicular cancer were under-reported. Minority groups (Black, Asian, Hispanic) reported lower rates of FH compared to the non-Hispanic white group (p<0.01). Respondents with less than 8 years education also had lower rates but this group only represented about 1 percent of the surveyed population.

### Quality Assessment of Studies

In three of the identified studies the characteristics of respondents and non-respondents were identified with the respondents being older than non-respondents.134–136 One study examined other sociodemographic factors, noting respondents were more likely to be Caucasian,135 while in another survey, respondents had slightly more FH recorded in their medical charts and were more likely to have performed BSE and mammography screening.136 Of the five studies that used cross-sectional surveys, the response rate was 80 percent or over in three studies, two of which were based in primary care,134,136 and the other was a population-based survey.139 Of the remaining two studies, a telephone survey had a 63 percent response rate138 and a primary care-based postal survey achieved a 27 percent response.135 In most studies the nature of the FH discussed or reported was not clearly identified, often just reported as dichotomous variables. Only four of the six studies actually took place in primary care offices, and three of these were based in practices within the greater Boston area.135,136,138 Representativeness of these surveys is also limited by response bias and recall bias, for example Murff et al.,136 recruited older women and the responders were more likely to have had mammography screening. Collectively, these issues limit the generalizability of the study findings; hence, caution is urged in applying this information to clinical situations in primary care.

### Conclusion

The evidence base for addressing Q5 is heterogeneous and limited tosix stud ies exploring the association between various factors and FH reporting, documentation and discussion. There was a paucity of evidence to help “operationalize” family history collection and use in primary care, for instance, procedures and systems to improve collection. However, there are certain patterns that maybe informative. Routine physical examinations offer an appropriate screening “turnstile” to collect FH. Further, women appeared better informants than men did and recently appointed physicians were more enthusiastic about discussing FH. There are also disparities in FH collection and reporting in underserved groups, specifically non-white ethic groups,136,139 those with lower educational status,139 and those on state health insurance.137 This is probably due to a combination of factors including poor recall by patients and difference in the nature of practitioners’ consultations with different groups. Two studies also briefly considered other pragmatic resource issues: the potential of incorporating the family history in electronic health records136 and extent to which discussing FH extended consultation time. The opportunity cost of systematically collecting family histories still needs to be explored.