# Methods

## Analytic Framework

The analytic framework is a schematic representation of the strategy for showing the relationships between the primary exposure, which is the collection of family history (FH), and the outcomes of interest for each research question (Q). Figure 1 shows the inter-relationships among the six research questions being addressed in this systematic review.

Figure 1 Analytic framework for the research questions evaluated in this review

Abbreviations: FH=family history; Q=question

The framework shows the logical connection between the research questions, commencing with the accuracy of clients reporting their family history (FH) (Q2). If we consider a key purpose for collecting family history, as a test to screen or identifying clients who might be at an altered risk for developing the same disease, then the selection of the optimal items that will comprise a comprehensive FH should be considered; evaluation of the evidence for those items that are most predictive of subsequent disease development is sought in (Q1). Evaluation of the evidence for the impact of collecting FH is addressed in the third research question (Q3). The potential for harmful outcomes as a result of collecting FH will also be addressed (Q4).

The context in which FH is collected and factors that may facilitate or hinder its collection also have bearing on the validity of collecting FH (Q5). These contextual factors (Q5) and those related to accuracy of reporting (Q2) may influence the optimal selection of items to be included within a set constituting adequate FH collection for risk assessment in a primary care setting (Q1). Following the systematic collection of FH in a population representative of primary care, the uptake of prevention, screening, and other interventions are important outcomes of benefit that may result. The strength of the evidence from studies addressing Q1 through Q5 will inform future directions for assessing the value of FH on common chronic diseases in the primary care setting (Q6).

### Search Strategy

Bibliographic databases searched for this review included: MEDLINE^®^, EMBASE^®^, CINAHL^®^, Cochrane Controlled Trials Register (CCTR)^®^, and PsycINFO. Years searched were 1995 to March 2, 2009 inclusive. Our broad based search was not restricted by disease type, and yielded a very large number of titles and abstracts; as such, we limited the search to 1995 forward. Detailed search strategies are listed in Appendix A. We reviewed a limited number of grey literature sites, including NCPEQ and the Center for Disease Control (CDC). In addition, we retrieved and evaluated references from eligible studies that were not captured in our search. Hand searching was not undertaken.

### Eligibility Criteria

A list of eligibility criteria was determined and standardized forms were developed in Systematic Review Software (SRS, 3.0, TrialStat Corporation, Ottawa, Ontario Canada) and Microsoft Excel for the purposes of this systematic review.

#### Publication Year, Type, and Language

##### Inclusion

Language: Only English language studies were eligible for all research questions. Publication Date: 1995 to March 2, 2009.

##### Exclusion

Publications that were editorials, letters, conference papers, comments, opinions, or abstract only

### Eligibility Criteria for Research Q1

#### Population Subjects

##### Inclusion

- General population in non-specialist setting
- Primary care patients in non-specialist setting
- Participants in organized screening programs not based on FH

##### Exclusion

- Patients undergoing or having completed genetic testing, whether positive or negative
- Participants selected because of higher than average risk of disease
- None of the disease groups of interest

#### Intervention

##### Inclusion

- Family history collection – any modality
- We delimited this research question based on the disease categories suggested by the OMAR Conference Planning Committee and in consultation with the Technical Expert Panel (TEP). These included
  - Cardiovascular diseases (including stroke and inherited childhood heart conditions)
  - Diabetes
  - Cancer (lung, breast, colorectal, ovarian, prostate)
  - Allergy and atopy (limited to asthma specifically, and atopic disease as a group)
  - Mental health disorders (major depression, mood disorders)

##### Exclusion

- Medical history without FH collection
- Family history collection about diseases other than those specified in the inclusion criteria

#### Comparator/Study Design

##### Inclusion

Any quantitative, analytic design, in which the association between one or more FH items (considered ‘exposure’) is examined in relation to current disease or future disease risk. With the exceptions of atopy, allergy and mental illness studies, associations were restricted to FH and outcome of the same condition (e.g., association of FH of colorectal cancer and incidence of colorectal cancer but not FH of lung cancer and incidence of colorectal cancer)

##### Exclusion

- Case control studies
- Case reports
- Qualitative designs

#### Outcome

##### Inclusion

- Prevalence or incidence of one of the disease conditions specified by the OMAR committee and the TEP (cardiovascular including stroke and inherited childhood heart conditions, diabetes, cancer, allergy and atopy and mental health disorders)
- Outcomes were restricted to clinically evident or routinely ascertainable disease outcomes. Table 1 details the specific outcomes within each disease category

Table 1 List of included and excluded outcomes for Question 1 by major disease categories

DISEASE CATEGORY | INCLUDE | EXCLUDE
Coronary artery disease (CAD) (synonyms: ischemc i heart disease, coronary heart disease) | - Angina; - (Acute) Myocardial infarction (AMI, MI); - Revascularization (CABG, angioplasty); - Heart failure secondary to CAD; - CAD death; - CAD (not otherwise specified) | - Coronary artery calcification; - Intimal media thickness; - Hypertension; - Aneurysm; - Peripheral vascular disease; - Valvular heart disease
Stroke (synonym: cerebrovascular accident) | - Clinically apparent stroke | - Transient ischemic attack; - Subarachnoid hemorrhage not otherwise specified; - Convulsions (not otherwise specified); - Dementia (not otherwise specified)
Childhood/inherited/congenital heart disease | - Hypertrophic obstructive cardiomyopathy; - Long QT syndrome
Depression and mood disorders | - Depression; - Bipolar affective disorder (also known as manic/depressive psychosis); - Schizophrenia; - Anxiety related disorders | - Other psychiatric conditions
Diabetes | - Type 1 diabetes; - Type 2 diabetes; - Gestational diabetes | - Impaired fasting glucose alone; - Impaired glucose tolerance alone; - Metabolic syndrome
Allergy and Asthma | - Asthma; - Atopic disease examined as an overall category (defined in reports as ‘atopic disease’ either as a general class of conditions or as a composite including at least two of atopic asthma/wheeze, allergic dermatitis, specific food intolerance, allergic rhinitis/sinusitis) | - Food intolerance alone; - Eczema alone; - Allergic rhinitis/sinusitis alone
Cancer | - Breast cancer; - Ovarian cancer; - Colorectal cancer; - Prostate cancer; - Lung cancer | - Other cancers

Abbreviations: CABG=coronary artery bypass graft; CAD=coronary artery disease; AMI=acute myocardial infarction; MI-myocardial infarction; QT interval=time between start of Q wave and end of the T Wave in the hearts’ electrical system

##### Exclusion

- Outcomes for diseases other than those listed in Table 1
- Pre-disease or outcomes
- Research-based outcomes not in routine clinical use

### Eligibility Criteria for Research Q2

#### Population

##### Inclusion

- General population
- Primary care patients
- Primary care providers (including family physicians, general internists, obstetricians, gynecologists, nurses, nurse practitioners, physicians assistants, nutritionists, and behavioralists)
- Patients from specialized disease centers

##### Exclusion

- Patients recruited that had genetic testing completed, whether positive or negative

#### Intervention

##### Inclusion

- Index Test: FH collected in any modality
- Reference Standard (verification of disease status in relatives) to include any of the following:
  - Death registries
  - Disease registries
  - Medical records
  - Direct contact with relatives
  - Confirmation by relatives’ physicians
  - Verification from research databases only if medical records were contained within them

##### Exclusion

- Index Test: Collection of medical history without FH
- Reference Standard
  - Verification of disease status in relatives that does not include the methods listed above
  - Studies where patient report of FH was the reference standard and the focus of the study was to compare differences with documentation in medical charts

#### Study Design

##### Inclusion

- Any quantitative design, comparative or non-comparative

##### Exclusion

- Case report

#### Outcomes

##### Inclusion

- Metrics of study accuracy
  - Sensitivity
  - Specificity
  - Positive predictive value
  - Negative predictive value
- Measures of completeness of FH collection
- Percent Agreement/Kappa as a measure of accuracy

##### Exclusion

- Studies where only true positives were reported, with no additional information to calculate sensitivity or specificity
- Studies that did not report any outcomes listed above
- Studies that evaluated test-retest reliability alone

### Eligibility Criteria for Research Q3

Consistent with the intent of the question, evidence of the highest methodological quality (direct evidence) was sought. Only studies where the intervention (systematic collection or use of FH) was contrasted to a comparator that did not use FH were sought. The comparator could be between groups (for example, usual care) or within groups (before and after intervention).

#### Population

##### Inclusion

- General population in non-specialist setting
- Primary care patients in non-specialist setting
- Primary care providers (including family physicians, general internists, obstetricians, gynecologists, nurses, nurse practitioners, physician assistants, nutritionists, and behavioralists)
- Participants in organized screening programs not based on FH

##### Exclusion

- Studies where the practitioner is specialist (e.g., geneticist, cancer surgeon, oncologist, cardiologist)
- Patients recruited on the basis of genetic testing whether results were positive or negative

#### Intervention

##### Inclusion

- Collection or use of FH collected in a systematic manner; can be in isolation or part of a multiplicative risk assessment

##### Exclusion

- Collection of FH is not part of the intervention (e.g., patients selected on the basis of increased risk including FH for another intervention)
- Family history is used as a selection criteria for study, not as an intervention

#### Comparator/Study Design

##### Inclusion

Primary studies of the following study designs

- Randomized controlled trials
- Non-randomized controlled trials
- Uncontrolled before-after studies

Comparators:

- No between group comparator
- Comparator group with no intervention
- Comparator group receiving preventive advice without provision of FH-based information

##### Exclusion

- Cohort studies
- Case-control studies
- Case series and case reports

#### Outcomes

##### Inclusion

- Disease-specific mortality
- Disease-specific morbidity
- Uptake of behavior or screening as a result of taking a FH and informing the subject of their risk

##### Exclusion

None of the outcomes listed above

### Eligibility Criteria for Research Q4

Consistent with the intent of the question, evidence of the highest methodological quality (direct evidence) was sought. Only studies where the intervention (systematic collection or use of FH) was contrasted to a comparator that did not use FH were sought. The comparator could be between groups (for example, usual care) or within groups (before and after intervention).

#### Population

##### Inclusion

- General population in non-specialist setting
- Primary care patients in non-specialist setting
- Primary care providers (including family physicians, general internists, obstetricians, gynecologists, nurses, nurse practitioners, physicians assistants, nutritionists, and behavioralists)
- Participants in organized screening programs not based on FH

##### Exclusion

- Studies where the practitioner is specialist (e.g., geneticist, cancer surgeon, oncologist, cardiologist)
- Patients recruited on the basis of genetic testing whether results were positive or negative

#### Intervention

##### Inclusion

- Collection or use of FH collected in a systematic manner; can be in isolation or part of a multiplicative risk assessment

##### Exclusion

- Collection of FH is not part of the intervention. e.g., patients selected on basis of increased risk including FH for another intervention
- Family history is used as a selection criteria for study, NOT intervention

#### Comparator/Study Design

##### Inclusion

Primary studies of the following study designs

- Randomized controlled trials
- Non-randomized controlled trials
- Uncontrolled before-after studies (non-controlled trials)

Comparators

- No comparator group
- Comparator group with no intervention
- Comparator group with intervention not based on FH collection or FH-based preventive advice

##### Exclusion

- Cohort studies
- Case-control studies
- Case series and case reports

#### Outcome

##### Inclusion

- Quality of life
- Family functioning
- Social functioning
- Psychological distress e.g., worry, anxiety, depression, inaccurate risk perception
- Related to the FH collection and/or use only, not to the resulting intervention

##### Exclusion

- Outcomes not listed above

### Eligibility Criteria for Research Q5

#### Population

##### Inclusion

- General population in non-specialist setting
- Primary care patients in non-specialist setting
- Primary care providers (including family physicians, general internists, obstetricians, gynecologists, nurses, nurse practitioners, physician assistants, nutritionists, and behavioralists)
- Participants in organized screening programs not based on FH

##### Exclusion

- Studies where the practitioner is a specialist (e.g., geneticist, cancer surgeon, oncologist, cardiologist)
- Patients recruited with genetic testing complete, whether positive or negative

#### Intervention

##### Inclusion

Factors (independent variables) that positively OR negatively affect either the collection and/or use of FH, or the extent and quality of FH collected or used. Factors can be patient-specific, practitioner-specific, and setting-specific. These include:

- Psychosocial
- Socio-demographic (e.g., ethnicity; gender)
- Financial
- Relationship of patient with healthcare provider (e.g., new provider/established provider)

##### Exclusion

- None

#### Comparator/Study Design

##### Inclusion

- Any quantitative design, comparative or non-comparative

##### Exclusion

- Any qualitative study design

#### Outcome

##### Inclusion

Self reported FH by patient or measure of FH collection or use. Metric to assess FH collection or use include:

- Attributes that determine if FH reported (either yes/no or extent of FH)
- Attributes that determine if FH discussed (either yes/no or extent of FH)
- Attributes that determine if FH used (either yes/no or extent of FH)

##### Exclusion

None

### Study Selection

A team of study assistants was trained to apply the eligibility criteria for screening the title and abstract lists and the full text papers. All levels of screening were done in web-based Systematic Review Software (SRS) (TrialStat Corporation, Ottawa, Ontario Canada). Standardized forms and a training manual explaining the criteria were developed and reviewed with the screeners (Appendix B). For the title and abstract phase, two reviewers evaluated each citation for eligibility. Articles were retrieved if either one of the reviewers judged it as meeting eligibility criteria or if there was insufficient information to determine eligibility. For screening of full text articles, two screeners came to consensus on the identification, selection, and abstraction of information. Disagreements that could not be resolved by consensus were resolved by one of our McMaster research team members.

### Data Extraction

Appropriate data collection forms were developed for use in SRS (Appendix B). All eligible studies from full text screening were abstracted onto a data form according to predetermined criteria. One data extractor transferred the data onto these forms, and another checked the answers for accuracy before they were entered into SRS. Data entries were verified by the investigators responsible for summarizing the different report results sections.

### Quality Assessment

Given the diversity of research questions and eligible study designs, we considered the assessment of quality separately for each research question. For Q1, the large number of studies were grouped by study design and disease types, which served in part, to stratify studies by similar risk for biases. The study designs for the eligible studies of Q1 were classified as longitudinal and cross sectional. Cohort studies where FH was assessed at the same point as disease outcome was ascertained were considered cross sectional studies. For quality assessment we selected questions on method of sampling, and participation rates for the cross sectional studies; we evaluated method of disease outcome ascertainment, method of family history ascertainment, and an accounting of withdrawals for all study designs (see Appendix B forms for the specification of the criteria).

For Q2, the Quality Assessment of Diagnostic Accuracy Assessment (QUADAS) was selected and all but four items within the 14 criteria were applicable for the “index test” of collecting FH. Appendix B details the criteria and the method of standardizing responses. Criteria from items 3, 4, 12, and 13 of the QUADAS were not applicable to collecting FH from informants and verifying the diseases in relatives. In applying these QUADAS items, we assumed that the index test (FH collection) and the reference test were equivalent across studies. Appendix B shows the modifications and interpretation of the QUADAS for this question.

There were two different designs among studies eligible for research Q3 and Q4; for the randomized clinical trials, the Jadad scale155 was used to evaluate internal validity. For the before after study design no formal scale was available, critical appraisal was undertaken for the risk of selection and outcome biases. For eligible cross sectional studies for research Q5, selection bias (method of sampling) and response bias were evaluated.

## Summarizing our Findings: Descriptive and Analytic Approaches

A qualitative descriptive approach was used to summarize study characteristics and outcomes for all research questions. Multiple publications on the same study cohort were grouped together and treated as a single study with the most current data reported for presentation of summary results. Standardized summary tables explaining important study population and population characteristics, as well as study results, were created.

Meta-analysis was not appropriate for any of the research questions. It was not undertaken for Q1 because of significant clinical heterogeneity across studies, and because many observations were compared within studies, therefore the studies were not completely independent. Similarly, it was not undertaken in Q2 because of significant clinical heterogeneity across studies, too few studies for some disease categories, or insufficient data (no measures of variance). There were an insufficient number of studies in Q3 and Q4 for meta-analysis. Clinical and methodological heterogeneity was significant for eligible studies in Q5.

For research Q1, the purpose of the analysis was to compare the discriminatory accuracy of specific FH items and definitions of ‘positive’ FH which might be used in routine clinical practice. The ideal method would have been a meta-regression analysis to assess the contribution of the different variables of interest (ancestry, lineage, age of onset, etc) to overall discriminatory accuracy. However, no studies were identified which permitted such an analysis. In order to address the research question, therefore, a simpler, alternative approach was developed. For each study, all definitions of ‘positive FH’ which were associated with analyzable data (see below) were recorded and, within disease condition, similar FH definitions (e.g., ‘mother’, ‘father’, ‘at least one 1DR’, etc.,) were grouped for comparison. We approached the definitions from a pragmatic clinical perspective, rather than epidemiological perspective so that in studies with multiple definitions we combined data from mutually exclusive categories into inclusive categories. For example, the category ‘affected mother’ included data from the categories ‘mother only’ and ‘both parents’. Thus, the category “affected mother” should generally be taken to mean, “affected mother, whether or not the father also affected.

We extracted the actual numbers of true and false positive and negative results (TP, FP, TN, and FN) according to these definitions, or estimated these numbers based on reported proportions. We calculated sensitivities, and specificities with the accompanying 95 percent confidence intervals (CI).

Recognizing the primary care context for the review, in which the time and resources available for FH taking may be very limited, we developed a categorization of FH definitions to reflect the ‘complexity’ of the task (Table 2). It is important to note that this initial attempt at categorization is based on a notion of ‘likely effort required’, not on any a priori notion of the information value of the pedigree itself. We suggest that the FH definition that combines ‘adequate’ predictive validity with least effort (lowest category) might be the most likely to be useful in routine primary care settings.

Table 2 Notional classification of family history items and definition of a positive family history

Category | General approach to FH collection | “Positive” FH | Example | Workload
A | Ask the most general question to identify one affected family member whose relationship does not need to be specified | One single relative affected by condition, relationship irrelevant | Does anyone in your family have the condition? | - Enquiry stops if patient recalls one affected relative; - Workload very low if approached as simple screening question; - Workload higher if approached by systematically working through pedigree to ascertain relatives’ status
B | Ask about 1–2 specific family members, and no others. | One or two defined relatives affected by condition | Do either of your parents have the condition? Does your brother have the condition? Did your mother have this condition? If so, do you also have a sister with it? | - Enquiry stops when affected/unaffected status of no more than 2 specified relatives is clarified; - Workload potentially very low
C | Ask about close family only | One or more first degree relatives (not pre-specified further) affected by condition | Does any member of your immediate family have the condition? Have any of your parents, brothers or sisters been affected by this condition? | - Enquiry stops when the minimum number of specified affected relatives is reached OR unaffected status of all first degree relatives clarified; - Workload depends on number of siblings and children, but enquiry limited by number of first degree relatives
D | Be ready to go beyond close family but do not consider lineage | One or more first and/or second, and/or [possibly] third degree relatives (but not pre- specified further) affected by condition | Have any of your immediate or broader family (aunts, uncles, grandparents, etc.) have the condition? | - Enquiry stops when minimum number of specified affected relatives is reached OR unaffected status of all relatives of interest is clarified; - Workload depends on number of relatives in close and extended family and how far FH criteria extend beyond first degree
E | Follow specific guidelines which define relevant FH history in a more complex manner or which go beyond affected relatives | More complex combination of numbers, degree of relationship, and/or lineage of relatives affected by condition, and/or considerations such as consanguinity | Have at least two immediate relatives from the same side of the family (i.e., excluding both parents but including one parent and a brother or sister or two of your brothers and sisters) been diagnosed with the condition? If not, has one immediate relative and at least two of your aunts, uncles, grandmother, grandfather, nieces or nephews (on the same side of the family) been diagnosed with the condition? If not, have at least three of your aunts, uncles, grandmother, grandfather, nieces, and/or nephews (on the same side of the family) been diagnosed with the condition? | - Enquiry stops when the criteria for positive FH are met OR the unaffected status of relatives of interest is clarified.; - Workload variable, depends on complexity of criteria and number of relatives potentially of interest

Abbreviations: FH=family history

Summary receiver operator characteristic (SROC) curves were estimated to assess the effect on accuracy of different FH definitions within each major disease group. The SROC curve mimics the receiver operator characteristic (ROC) curve and is a way to measure the diagnostic accuracy across different studies. We estimated the area under the curve (AUC) and the index Q* and their standard errors. The value of Q* indicates overall accuracy by finding where sensitivity and specificity are equal. Since Q* is defined by the point where sensitivity and specificity are equal, Q* may not address the clinical usefulness of the test when sensitivity and specificity are not equally important in practice. Note that a minimum of three studies with the same FH definition would be required for this computation. Statistical analyses were carried out using Stata/SE 8.0 for Windows (Stata Corporation) or MetaDiSc.156 Additionally, data points entered into the analyses had to be independent; as such, we selected the most inclusive FH definition within each family history category (Table 2). For example, data from a single study reporting values for greater than or equal to one parent, mother, and father would not be independent; the data from greater than one parent was selected to include in the SROC analyses.

## Peer Review Process

The partner organization, TOO, research team, and members of the TEP identified potential peer reviewers. The MU-EPC compiled a list of these reviewers, all of whom were approved by the AHRQ prior to the circulation of the draft report.

A draft version of this report was circulated to 10 peer reviewers (see Appendix E). The reviewers represented clinicians and expert in family medicine/primary care, cancer, cardiovascular disease, diabetes, asthma, genetics, and family history. The reviewers were provided with a standardized form to solicit feedback on the methods of the review, the presentation of the information and the interpretation of the results. Where possible, comments and suggestions were incorporated.