# Introduction

## Background

According to the Centers for Disease Control and Prevention, almost half of Americans live with at least one chronic condition, and chronic diseases account for 70 percent of all deaths in the United States, one third of potential years of life lost before 65, and three quarters of medical care costs.140 Although the role of important risk factors such tobacco, nutrition, and physical activity are well known, there are many unknown factors that contribute to risk and which prevent completely accurate individualized risk assessment across a range of diseases. Nevertheless, it is possible that a traditional, ‘low tech’ approach to risk assessment–family history–might be practical and useful for widespread application, to assist in identifying particular risks carried by individuals, in order to target interventions and efforts on disease prevention. Family history (FH) represents the integration of shared genomic and environmental risk factors.1 First degree relatives (1DRs) share half their genomic information (roughly one copy of 30–50,000 genes), and so their disease experience may offer a clue to shared susceptibilities, even in the absence of a complete understanding of the molecular etiology of a given condition. While FH assessment is a core approach in clinical genetics, FH may offer much more than the possibility of identifying relatively rare inherited diseases which follow a Mendelian inheritance pattern. Approached as a ‘black box’ FH may provide information on the influence of genetic variants which, collectively, act to increase or decrease disease susceptibility, and on other familial factors which alter risk (such as shared behaviors and lifestyles).

Family history may therefore be a cost effective way of tapping into ‘integrated’ disease risk information.141 For most common chronic diseases, the impact of a positive FH has been recognized. For example, a population-based study in Utah observed that 14 percent of families accounted for 72 percent of the premature coronary heart disease (CHD) in the state, and 11 percent of families accounted for 86 percent of premature cerebrovascular disease;142 in another study 30 percent of middle-aged British men who report a FH of CHD experience a 71 percent excess risk of CHD themselves over 10 years.143 Further, we are aware of the individual roles of obesity and FH in predicting the development of diabetes, but in combination, the predictive value increases from around 20 to 40 percent.

Support for this approach also comes from a detailed meta-analysis,144 in which the association between having one or more 1DRs and risk of a number of common, complex disorders was convincingly demonstrated.

However, there are important issues that need to be addressed regarding the overall utility of using FH information in primary care settings. The first issue relates to the capture of FH information in itself. For FH information to be useful, there should be some confidence that patients are able to report it accurately and consistently. This has been addressed for some cancers in a previous review.145 Secondly, there should be evidence that health professionals in primary care can capture such information accurately. Previous reviews145,146 have examined FH tools and demonstrated that the systematic use of a FH tool improves accuracy and completeness of information capture. It appears that the crucial issue is use of a tool, rather than its specific format, although further research may clarify whether any particular attributes (such as patient-completed versus professional-completed, or electronic versus paper) offer specific advantages for use in particular settings. An important issue which needs to be addressed is the ‘minimum FH dataset’ necessary for application in primary care settings for chronic disease risk prediction.147–151 It is important to bear in mind that primary care practitioners face constraints in relation to capturing FH information,152 and cannot necessarily replicate the practice of genetics specialists in completing detailed, three generational pedigrees.

A broader, but crucial question is that of the overall benefits and harms of capturing FH information. Like any health care intervention, FH-based risk assessment carries resource implications and opportunity costs. Thus, its impact on health outcomes, both beneficial and harmful, should be assessed objectively in order to promote evidence-informed practice and policy.

## Overall Evaluation Approach

In approaching these questions, we have borrowed from a range of evaluative frameworks including: methods developed in diagnostic and screening test research (applied to assessing individual FH items for their predictive validity, and for the assessment of accuracy of FH reporting): methods for the assessment of the effectiveness and safety of clinical interventions (applied to FH taking as a deliberate clinical intervention); and classical epidemiological methods (applied to the assessment of factors which promote or hinder FH taking as a routine clinical activity).

## Scope and Purpose of the Systematic Review

This systematic review addresses six research questions relating to the analytic validity, the clinical validity, and the clinical utility of routinely using FH information in risk assessment for complex disorders, as follows.

1. What are the key elements of a family history in a primary care setting for the purposes of risk assessment for common diseases?
2. What is the accuracy of the family history, and under what conditions does the accuracy vary?
3. What is the direct evidence that routinely getting a family history will improve health outcomes for the patient and/or family?
4. What is the direct evidence that routinely getting a family history will result in adverse outcomes for the patient and/or family?
5. What are the factors that encourage or discourage obtaining and using a family history?
6. What are future research directions for assessing the value of family history for common diseases in the primary care setting?

Regarding research question 1, the specific disease categories of interest were:

- breast, ovarian, colorectal, prostate, and lung cancers
- cardiovascular and heart disease
- stroke
- diabetes
- asthma and allergies (atopic disease)
- major depression and mood disorders

in addition, key elements for consideration were information relating to:

- ancestry
- number of affected or unaffected relatives
- lineage
- age of onset
- sex or gender
- relationship (first degree, second degree)

Question 6 is addressed by drawing together the evidence from questions 1 to 5 and therefore is not evaluated separately. The focus of this review is on using FH in primary care contexts, and as an intervention mainly for chronic disease risk assessment in large population groups, not assessment of rare genetic disorders in high risk groups. This has driven the eligibility criteria for studies towards:

- study populations with the range of disease risk seen in primary care and general settings
- study settings where primary care providers such as family physicians, internists, nurse practitioners, and obstetricians are taking family histories and assessing risk
- family history taking as an intervention carried out by primary care practitioners and directed primarily towards chronic disease risk assessment and prevention as an end in itself
- chronic disease prevention interventions evaluated in primary care or general populations with an inherent range of disease risks, but not selected because of special high risk (genetic or otherwise)

The focus on study populations “unselected” for high risk implies groups of participants, which represent a full range of risks, potentially from very low to very high, by definition with clustering around an “average” value. These populations reflect the context of professional and patient decision-making in primary care - patients with a wide range of risks are encountered, but most are neither particularly high nor particularly low risk. This situation is distinguished from that where patients and their providers already have reason to suspect high disease risk, as such populations are more homogenous and are designed to exclude individuals who are likely to be average and low risk. While findings from ‘unselected’ populations may possibly be applicable to high risk groups, the converse cannot be assumed.

Family history taking is a health care intervention and its evaluation requires as much attention to potential bias as any other intervention. An important potential confounder in assessing this intervention is pre-existing awareness of family illness. Living with a serious disease within a family can influence risk perceptions and health behaviors,153,154 quite independently of any intervention by a health professional. This means that the effect of FH taking as a deliberate clinical activity can only be meaningfully assessed using well-designed studies that can address confounding and bias. Family history taking is also an inherently complex intervention and needs to be separated from other activities, such as genetic testing.