# Technical Expert Panel and Peer Reviewers

## Task Order Officer

- Supriya Janakiraman, M.D., M.P.H.
- Staff Service Fellow, Center for Outcomes and Evidence AHRQ
- Rockville, MD USA

## Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives are sought. Divergent and conflicted opinions are common and perceived as health scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design and/or methodologic approaches do not necessarily represent the views of individual technical and content experts.

- Al Berg, M.D., M.P.H., Official representativ e on TEP for partners
- Professor
- Department of Family Medicine
- University of Washington School of Medicine

- Lisa Madlensky, Ph.D.
- Moores UCSD Cancer Center
- University of California

- Louise S. Acheson, M.D., M.S.
- Department of Family Medicine
- Case Western Reserve University

- Wylie Burke, M.D., Ph.D.
- Professor and Chair
- Department of Medical History and Ethics
- University of Washington

## Peer Reviewers

Peer reviewer comments on a preliminary draft of this report were considered by the EPC in preparation of this final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Joy Larsen Haidle, M.S., C.G.C.
- Genetic Counselor
- Hubert H. Humphrey Cancer Center
- Robbinsdale, MN

- Ted Adams PhD MPH
- Research professor, Cardiovascular Genetics Division
- University of Utah School of Medicine
- Salt Lake City, UT

- Doug Campos-Outcalt M.D, M.P.A.
- Associate Chair
- University of Arizona College of Medicine
- Department of Family and Community Medicine
- Phoenix, AZ

- Karen Edwards M.D.
- Associate Professor, Epidemiology
- Department of Epidemiology
- University of Washington
- Seattle, WA

- Jon Emery M.D.
- Department of General Practice
- University of Western Australia
- Claremont, WA
- Australia

- Kent McKelvey
- Assistant Professor, Family and Preventive Medicine and
- Director of Cancer Genetics Services
- University of Arkansas
- Little Rock, AR

- Kristin Peterson Oehlke MS CGC
- State Genomics Coordinator
- Minnesota Department of Health
- St. Paul, MN

- Jon Tilburt M.D
- Division of General Internal Medicine
- The Program in Professionalism and Bioethics
- Mayo Clinic
- Rochester, MN

- Barbara P. Yawn, M.D., M.Sc, FAAFP
- Director of Research
- Department of Research and Education
- Olmsted Medical Center
- Rochester, MN

- Carrie Zabel M.S., C.G.C
- Genetic counselor
- Genomics Education Program
- Mayo Clinic
- Rochester, MN