# Excluded Studies

EUROASPIRE. A European Society of Cardiology survey of secondary prevention of coronary heart disease: principal results. EUROASPIRE Study Group. European Action on Secondary Prevention through Intervention to Reduce Events. [erratum appears in Eur Heart J 1998 Feb;19(2):356–7]. Eur Heart J. Oct. 1997;18(10):1569-82. Excluded because no eligible outcomes presented. [pmid: 9347267].
Risk factors for breast cancer in elderly women are similar to those for younger post-menopausal women. Evid Base Healthc Publ Health. 2005;9(3):245-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Aasvee K, Kurvinen E, Sundvall J, et al. Aggregation of lipoprotein and inflammatory parameters in families with a history of premature myocardial infarction: the Tallinn myocardial infarction study. Clin Chem Lab Med. 2008;46(11):1602-8. Excluded because no eligible outcomes presented. [pmid: 19012525].
Abaitua FR, Martinez JI, Lopez RE, et al. Family history as a predictor for childhood hyperlipidemia. Cardiovasc Risk Factors. 1996;6(5):277-83. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Abchee A, Puzantian H, Azar ST, et al. Predictors of coronary artery disease in the Lebanese population. Thromb Res. 2006;117(6):631-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15985286].
Aberg N, Sundell J, Eriksson B, et al. Prevalence of allergic diseases in schoolchildren in relation to family history, upper respiratory infections, and residential characteristics. Allergy. 1996;51(4):232-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8792919].
Acheson LS, Zyzanski SJ, Stange KC, et al. Validation of a self-administered, computerized tool for collecting and displaying the family history of cancer. J Clin Oncol. Dec. 1. 2006;24(34):5395-402. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17088568].
Ackermann S, Lux MP, Fasching PA, et al. Acceptance for preventive genetic testing and prophylactic surgery in women with a family history of breast and gynaecological cancers. Eur J Cancer Prev. Dec. 2006;15(6):474-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17106324].
Acton RT, Burst NM, Casebeer L, et al. Knowledge, attitudes, and behaviors of Alabama's primary care physicians regarding cancer genetics. Acad Med. Aug. 2000;75(8):850-2. Excluded because no eligible outcomes presented. [pmid: 10965867].
Acton RT, Barton JC, Passmore LV, et al. Accuracy of Family History of Hemochromatosis or Iron Overload: The Hemochromatosis and Iron Overload Screening Study. Clin Gastroenterol Hepatol. 2008;6(8):934-8. Excluded because not an eligible population. [pmid: 18585964].
Adamson AJ, Foster E, Butler TJ, et al. Non-diabetic relatives of Type 2 diabetic families: dietary intake contributes to the increased risk of diabetes. Diabet Med. Dec. 2001;18(12):984-90. Excluded because no eligible outcomes presented. [pmid: 11903398].
Aggarwal AN, Chaudhry K, Chhabra SK, et al. Prevalence and risk factors for bronchial asthma in Indian adults: a multicentre study. Indian J Chest Dis Allied SciI. Jan. 2006;48(1):13-22. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Aghassi-Ippen M, Green MS, Shohat T. Familial risk factors for breast cancer among Arab women in Israel. Eur J Cancer Prev. Aug. 2002;11(4):327-31. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12195158].
Ahsan H, Neugut AI, Garbowski GC, et al. Family history of colorectal adenomatous polyps and increased risk for colorectal cancer. Ann Intern Med. Jun. 1. 1998;128(11):900-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9634428].
Aitken JF, Bain CJ, Ward M, et al. Risk of colorectal adenomas in patients with a family history of colorectal cancer: some implications for screening programmes. Gut. Jul. 1996;39(1):105-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8881819].
Ajay VS, Prabhakaran D, Jeemon P, et al. Prevalence and determinants of diabetes mellitus in the Indian industrial population. Diabet Med. 2008;25(10):1187-94. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 19046197].
Akesson K, Nystrom L, Farnkvist L, et al. Increased risk of diabetes among relatives of female insulin-treated patients diagnosed at 15–34 years of age. Diabet Med. Nov. 2005;22(11):1551-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16241921].
Akimova EV, Bogmat LF. Premature coronary heart disease: the influence of positive family history on platelet activity in vivo in children and adolescents (family study). J Cardiovasc Risk. Feb. 1997;4(1):13-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9215515].
Akkurt I, Sumer H, Ozsahin SL, et al. Prevalence of asthma and related symptoms in Sivas, Central Anatolia. J Asthma. 2003;40(5):551-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14529105].
Al Bassam MKS, Al Awar S, Khan F, et al. Universal screening strategy for gestational diabetes mellitus: The experience of Tawam Hospital. Emirates Medical Journal. 2007;25(3):307-10. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Al Habsi H, Lim JNW, Chu CE, et al. Factors influencing the referrals in primary care of asymptomatic patients with a family history of cancer. Genet Med. 2008;10(10):751-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18813138].
Al Mahroos F, McKeigue PM. High prevalence of diabetes in bahrainis: Associations with ethnicity and raised plasma cholesterol. Diabetes Care. 1998;21(6):936-42. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9614611].
Al Rukban MO, Al Sughair AM, Al Bader BO, et al. Management of hypertensive patients in primary health care setting, auditing the practice. Saudi Med J. 2007;28(1):85-90. Excluded because family history not collected. [pmid: 17206296].
Al Saeed WY, Al Dawood KM, Bukhari IA, et al. Risk factors and comorbidity of skin disorders among female schoolchildren in eastern Saudi Arabia. Invest Clin. 2007;48(2):199-212. Excluded because no eligible outcomes presented. [pmid: 17598643].
Al Safi SA, Aboul-Enein FH, Aboul-Enein BH, et al. Influence of family history and lifestyle on blood pressure and heart rate in young adults in Jordan. Public Health. Nov. 2006;120(11):1027-32. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17010398].
Al Shafaee MA, Al Shukaili S, Rizvi SGA, et al. Knowledge and perceptions of diabetes in a semi-urban Omani population. BMC Public Health. 2008;8:249. Excluded because no eligible outcomes presented. [pmid: 18644163].
Al Shaibani H, Bu-Alayyan S, Habiba S, et al. Risk factors of breast cancer in Kuwait: Case-control study. Iranian Journal of Medical Sciences. 2006;31(2):61-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Alberto VO, Harocopos CJ, Patel AA, et al. Family and personal history in colorectal cancer patients: what are we missing?. Colorectal Dis. Sep. 2006;8(7):612-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16919116].
Aldington S, Pritchard A, Perrin K, et al. Prolonged seated immobility at work is a common risk factor for venous thromboembolism leading to hospital admission. Intern Med J. 2008;38(2):133-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18290829].
Allan CL, Flett B, Dean HJ. Quality of life in first nation youth with type 2 diabetes. Matern Child Health J. 2008;12(Suppl 1):S103-S109. Excluded because no eligible outcomes presented.
Allinson V. Breast cancer: evaluation of a nurse-led family history clinic. J Clin Nurs. Sep. 2004;13(6):765-6. Excluded because no eligible outcomes presented. [pmid: 15317517].
Almendingen K, Hofstad B, Vatn MH. Does a family history of cancer increase the risk of occurrence, growth, and recurrence of colorectal adenomas?. Gut. May. 2003;52(5):747-51. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12692063].
Altobelli E, Chiarelli F, Valenti M, et al. Family history and risk of insulin-dependent diabetes mellitus: a population-based case-control study. Acta Diabetol. Apr. 1998;35(1):57-60. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9625291].
Amberger N, Masuhr F, Valdueza JM, et al. A negative personal and family history for venous thrombotic events is not sufficient to exclude thrombophilia in patients with cerebral venous thrombosis. Eur J Neurol. Aug. 2004;11(8):555-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15272901].
Ammari F, Batieha A, Jaddou PHH, et al. A natural history of impaired glucose tolerance in North Jordan. Pract Diabetes Int. 1998;15(5):139-40. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Andermann AAJ, Watson EK, Lucassen AM, et al. The opinions, expectations and experiences of women with a family history of breast cancer who consult their GP and referred to secondary care. Community Genet. 2001;4(4):239-43. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12107353].
Andersen MR, Peacock S, Nelson J, et al. Worry about ovarian cancer risk and use of ovarian cancer screening by women at risk for ovarian cancer. Gynecol Oncol. Apr. 2002;85(1):3-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11925113].
Andersen MR, Bowen D, Yasui Y, et al. Awareness and concern about ovarian cancer among women at risk because of a family history of breast or ovarian cancer. Am J Obstet Gynecol. Oct. 2003;189(4 Suppl):S42-S47. Excluded because no eligible outcomes presented. [pmid: 14586320].
Andersen MR, Smith R, Meischke H, et al. Breast cancer worry and mammography use by women with and without a family history in a population-based sample. Cancer Epidemiol Biomarkers Prev. Apr. 2003;12(4):314-20. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12692105].
Anderson E, Berg J, Black R, et al. Predicting breast cancer risk: Implications of a “weak” family history. Fam Cancer. 2008;7(4):361-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18560993].
Anderson WF, Matsuno RK, Sherman ME, et al. Estimating age-specific breast cancer risks: A descriptive tool to identify age interactions. Cancer Causes Control. 2007;18(4):439-47. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17216325].
Andersson SO, Baron J, Bergstrom R, et al. Lifestyle factors and prostate cancer risk: A case-control study in Sweden. Cancer Epidemiol Biomarkers Prev. 1996;5(7):509-13. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8827354].
Andresdottir MB, Sigurdsson G, Sigvaldason H, et al. Fifteen percent of myocardial infarctions and coronary revascularizations explained by family history unrelated to conventional risk factors. The Reykjavik Cohort Study. Eur Heart J. Nov. 2002;23(21):1655-63. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12398822].
Andrieu N, Launoy G, Guillois R, et al. Estimation of the familial relative risk of cancer by site from a French population based family study on colorectal cancer (CCREF study). Gut. Sep. 2004;53(9):1322-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15306593].
Aprikian AG, Bazinet M, Plante M, et al. Family history and the risk of prostatic carcinoma in a high risk group of urological patients. J Urol. Aug. 1995;154(2:Pt 1):404-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 7541856].
Arabia G, Grossardt BR, Geda YE, et al. Increased risk of depressive and anxiety disorders in relatives of patients with Parkinson disease. Arch Gen Psychiatry. Dec. 2007;64(12):1385-92. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18056546].
Arif AA, Venati G, Bordes TF, et al. Correlates of physician visits among children and adolescents in West Texas: Effects of hyperglycemia symptoms. J Rural Health. 2004;20(3):296-300. Excluded because no eligible outcomes presented. [pmid: 15298106].
Armstrong K, Weber B, Ubel PA, et al. Interest in BRCA1/2 testing in a primary care population. Prev Med. 2002;34(6):590-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12052018].
Arsov T, Miladinova D, Spiroski M. Factor V Leiden is associated with higher risk of deep venous thrombosis of large blood vessels. Croat Med J. 2006;47(3):433-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16758522].
Ashton KA, Proietto A, Otton G, et al. The influence of the Cyclin D1 870 G>A polymorphism as an endometrial cancer risk factor. BMC Cancer. Sep. 2008;8:272. Excluded because no eligible outcomes presented. [pmid: 18822177].
Askling J, Dickman PW, Karlen P, et al. Family history as a risk factor for colorectal cancer in inflammatory bowel disease. Gastroenterology. May. 2001;120(6):1356-62. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11313305].
Auranen A, Grenman S, Makinen J, et al. Borderline ovarian tumors in Finland: epidemiology and familial occurrence. Am J Epidemiol. Sep. 15. 1996;144(6):548-53. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8797514].
Azadeh S, Moghimi-Dehkordi B, Fatem SR, et al. Colorectal cancer in Iran: an epidemiological study. Asian Pac J Cancer Prev. Jan. 2008;9(1):123-6. Excluded because no eligible outcomes presented. [pmid: 18439090].
Babaoglu K, Hatun S, Arslanoglu I, et al. Evaluation of glucose intolerance in adolescents relative to adults with type 2 diabetes mellitus. J Pediatr Endocrinol. Nov. 2006;19(11):1319-26. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Backlund AB, Perzanowski MS, Platts-Mills T, et al. Asthma during the primary school ages - Prevalence, remission and the impact of allergic sensitization. Allergy. 2006;61(5):549-55. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16629783].
Bai Y, Gao YT, Deng J, et al. Risk of prostate cancer and family history of cancer: a population-based study in China. Prostate Cancer Prostatic Dis. 2005;8(1):60-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15643451].
Bajdik CD, Fang R, Band PR, et al. Do work-related breast cancer risks in pre-menopausal women depend on family history?. Chronic Dis Can. 2004;25(3–4):147-51. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15841855].
Baldwin RC, Tomenson B. Depression in later life. A comparison of symptoms and risk factors in early and late onset cases. Br J Psychiatry. Nov. 1995;167:649-52. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8564322].
Bank I, van de Poel MH, Coppens M, et al. Absolute annual incidences of first events of venous thromboembolism and arterial vascular events in individuals with elevated FVIII:c. A prospective family cohort study. Thromb Haemost. Nov. 2007;98(5):1040-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18000609].
Bankhead C, Emery J, Qureshi N, et al. New developments in genetics-knowledge, attitudes and information needs of practice nurses. Fam Pract. Oct. 2001;18(5):475-86. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11604367].
Bao W, Srinivasan SR, Wattigney WA, et al. The relation of parental cardiovascular disease to risk factors in children and young adults. The Bogalusa Heart Study. Circulation. Jan. 15. 1995;91(2):365-71. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 7805239].
Bao W, Srinivasan SR, Valdez R, et al. Longitudinal changes in cardiovascular risk from childhood to young adulthood in offspring of parents with coronary artery disease: The Bogalusa heart study. JAMA. 1997;278(21):1749-54. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9388151].
Barlow-Stewart K, Soo SY, Meiser B, et al. Toward cultural competence in cancer genetic counseling and genetics education: Lessons learned from Chinese-Australians. Genet Med. 2006;8(1):24-32. Excluded because not an eligible study design. [pmid: 16418596].
Barone B, Rodacki M, Zajdenverg L, et al. Family history of type 2 diabetes is increased in patients with type 1 diabetes. Diabetes Res Clin Practice. Oct. 2008;82(1):e1-e4. Excluded because no eligible outcomes presented.
Barrison AF, Smith C, Oviedo J, et al. Colorectal cancer screening and familial risk: a survey of internal medicine residents' knowledge and practice patterns. Am J Gastroenterol. Jun. 2003;98(6):1410-6. Excluded because family history not collected. [pmid: 12818289].
Barth JA, Deckelbaum RJ, Starc TJ, et al. Family history of early cardiovascular disease in children with moderate to severe hypercholesterolemia: relationship to lipoprotein (a) and low-density lipoprotein cholesterol levels. J Lab Clin Med. Mar. 1999;133(3):237-44. Excluded because no eligible outcomes presented. [pmid: 10072255].
Basit A, Hakeem R, Hydrie MZ, et al. Fatness, lipids, insulin sensitivity, and life style of children from high and low risk families. J Ayub Med Coll Abbottabad. Jul. 2003;15(3):6-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14727329].
Basit A, Hakeem R, Hydrie MZI, et al. Relation between family history, obesity and risk for diabetes & heart disease in Pakistani children. Pakistan J Med Sci. 2004;20(4):296-302. Excluded because no eligible outcomes presented.
Bastani R, Maxwell AE, Bradford C, et al. Tailored risk notification for women with a family history of breast cancer. Prev Med. Nov. 1999;29(5):355-64. Excluded because not an eligible population. [pmid: 10564627].
Bayram I, Guneser-Kendirli S, Yilmaz M, et al. The prevalence of asthma and allergic diseases in children of school age in Adana in Southern Turkey. Turk J Pediatr. 2004;46(3):221-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15503474].
Bazzazi H, Gharagozlou M, Kassaiee M, et al. The prevalence of asthma and allergic disorders among school children in Gorgan. J Res Med Sci. 2007;12(1):28-33. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Beebe-Dimmer JL, Wood DP Jr, Gruber SB, et al. Risk perception and concern among brothers of men with prostate carcinoma. Cancer. Apr. 1. 2004;100(7):1537-44. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15042690].
Beebe-Dimmer JL, Drake EA, Dunn RL, et al. Association between family history of prostate and breast cancer among African-American men with prostate cancer. Urology. Nov. 2006;68(5):1072-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17095075].
Beji NK, Reis N. Risk factors for breast cancer in Turkish women: a hospital-based case-control study. Eur J Cancer Care. Mar. 2007;16(2):178-84. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Benazzi F. Unipolar depression with bipolar family history: Links with the bipolar spectrum. Psychiatry Clin Neurosci. 2003;57(5):497-503. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12950704].
Benazzi F. Bipolar II disorder family history using the family history screen: findings and clinical implications. Compr Psychiatry. Mar. 2004;45(2):77-82. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14999656].
Benhamiche-Bouvier AM, Lejeune C, Jouve JL, et al. Family history and risk of colorectal cancer: implications for screening programmes. J Med Screen. 2000;7(3):136-40. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11126162].
Benjamin C, Booth K, Ellis I. A prospective comparison study of different methods of gathering self-reported family history information for breast cancer risk assessment. J Genet Couns. 2003;12(2):151-70. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Bennett KE, Howell A, Evans DG, et al. A follow-up study of breast and other cancers in families of an unselected series of breast cancer patients. Br J Cancer. Mar. 4. 2002;86(5):718-22. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11875732].
Bensen JT, Li R, Hutchinson RG, et al. Family history of coronary heart disease and pre-clinical carotid artery atherosclerosis in African-Americans and whites: the ARIC study: Atherosclerosis Risk in Communities. Genet Epidemiol. 1999;16(2):165-78. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10030399].
Bergfeldt K, Rydh B, Granath F, et al. Risk of ovarian cancer in breast-cancer patients with a family history of breast or ovarian cancer: a population-based cohort study. Lancet. Sep. 21. 2002;360(9337):891-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12354469].
Bergmann RL, Diepgen TL, Kuss O, et al. Breastfeeding duration is a risk factor for atopic eczema. Clin Exp Allergy. Feb. 2002;32(2):205-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11929483].
Bergstrom E, Hernell O, Persson LA, et al. Serum lipid values in adolescents are related to family history, infant feeding, and physical growth. Atherosclerosis. Sep. 1995;117(1):1-13. Excluded because no eligible outcomes presented. [pmid: 8546746].
Bermejo JL, Hemminki K. Familial risk of cancer shortly after diagnosis of the first familial tumor. J Natl Cancer Inst. Nov. 2. 2005;97(21):1575-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16264177].
Bertuzzi M, Negri E, Tavani A, et al. Family history of ischemic heart disease and risk of acute myocardial infarction. Prev Med. Sep. 2003;37(3):183-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12914823].
Bhatia S, Pratt CB, Sharp GB, et al. Family history of cancer in children and young adults with colorectal cancer. Med Pediatr Oncol. Nov. 1999;33(5):470-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10531571].
Bindler RM, Short RA, Cooney SK, et al. Interventions to decrease cardiovascular risk factors in children: The Northwest Pediatric Heart Project. National Academies of Practice Forum: Issues in Interdisciplinary Care. Jan. 2000;2(1):43-8. Excluded because no eligible outcomes presented.
Bjerg A, Hedman L, Perzanowski MS, et al. Family history of asthma and atopy: in-depth analyses of the impact on asthma and wheeze in 7- to 8-year-old children. Pediatrics. Oct. 2007;120(4):741-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17908760].
Bloom JR, Stewart SL, Oakley-Girvans I, et al. Family history, perceived risk, and prostate cancer screening among African American men. Cancer Epidemiol Biomarkers Prev. Nov. 2006;15(11):2167-73. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17119042].
Bock CH, Peyser PA, Montie JE, et al. Decreasing age at prostate cancer diagnosis over successive generations in prostate cancer families. Prostate. Jun. 15. 2005;64(1):60-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15651090].
Bodner C, Godden D, Ross S, et al. Bronchial hyperresponsiveness and adult onset wheeze: the influence of atopy. Eur Respir J. Aug. 1999;14(2):335-8. Excluded because no eligible outcomes presented. [pmid: 10515410].
Boer JM, Feskens EJ, Verschuren WM, et al. The joint impact of family history of myocardial infarction and other risk factors on 12-year coronary heart disease mortality. Epidemiology. Nov. 1999;10(6):767-70. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10535794].
Bohme M, Wickman M, Lennart NS, et al. Family history and risk of atopic dermatitis in children up to 4 years. Clin Exp Allergy. Sep. 2003;33(9):1226-31. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12956743].
Boice JD Jr, Mandel JS, Doody MM. Breast cancer among radiologic technologists. JAMA. Aug. 2. 1995;274(5):394-401. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 7616635].
Boilesen AE, Bisgaard ML, Bernstein I. Risk of gynecologic cancers in Danish hereditary non-polyposis colorectal cancer families. Acta Obstet Gynecol Scand. 2008;87(11):1129-35. Excluded because not an eligible population. [pmid: 18972272].
Boles RG, Burnett BB, Gleditsch K, et al. A high predisposition to depression and anxiety in mothers and other matrilineal relatives of children with presumed maternally inherited mitochondrial disorders. Am J Med Genet Neuropsychiatr Genet. 2005;137(1):20-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Bonduel M, Hepner M, Sciuccati G, et al. Prothrombotic abnormalities in children with venous thromboembolism. J Pediatr Hematol Oncol. 2000;22(1):66-72. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10695825].
Bor AS, Rinkel GJ, Adami J, et al. Risk of subarachnoid haemorrhage according to number of affected relatives: a population based case-control study. Brain. Oct. 2008;131(Pt:10):10-5. Excluded because no eligible outcomes presented.
Borio R, Forini N, Salvadori P, et al. Risk versus benefit in mammographic screening procedures. Physica Medica. 1997;13(4):173-80. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Borres MP, Bjorksten B. Peripheral blood eosinophils and IL-4 in infancy in relation to the appearance of allergic disease during the first 6 years of life. Pediatr Allergy Immunol. 2004;15(3):216-20. Excluded because no eligible outcomes presented. [pmid: 15209953].
Bosken CH, Hunt WC, Lambert WE, et al. A parental history of asthma is a risk factor for wheezing and nonwheezing respiratory illnesses in infants younger than 18 months of age. Am J Respir Crit Care Med. Jun. 2000;161(6):1810-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10852749].
Bosson J-L, Pouchain D, Bergmann J-F. A prospective observational study of a cohort of outpatients with an acute medical event and reduced mobility: Incidence of symptomatic thromboembolism and description of thromboprophylaxis practices. J Intern Med. 2006;260(2):168-76. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16882282].
Bottorff JL, Ratner PA, Balneaves LG, et al. Women's interest in genetic testing for breast cancer risk: the influence of sociodemographics and knowledge. Cancer Epidemiol Biomarkers Prev. Jan. 2002;11(1):89-95. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11815405].
Boucher KM, Kerber RA. Measures of familial aggregation as predictors of breast-cancer risk. J Epidemiol Biostat. 2001;6(5):377-85. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11822727].
Boulton TJ, Cockington RA, Hamilton-Craig I, et al. A profile of heart disease risk factors and their relation to parents' education, fathers' occupation and family history of heart disease in 843 South Australian families: the Adelaide Children's WHO Collaborative Study. J Paediatr Child Health. Jun. 1995;31(3):200-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 7669380].
Boutet K, Malo J-L, Ghezzo H, et al. Airway hyperresponsiveness and risk of chest symptoms in an occupational model. Thorax. 2007;62(3):260-4. Excluded because no eligible outcomes presented. [pmid: 16893948].
Boutin-Foster C, Ogedegbe G, Ravenell JE, et al. Ascribing meaning to hypertension: A qualitative study among African Americans with uncontrolled hypertension. Ethn Dis. 2007;17(1):29-34. Excluded because not an eligible study design. [pmid: 17274206].
Boutron MC, Faivre J, Quipourt V, et al. Family history of colorectal tumours and implications for the adenoma-carcinoma sequence: a case control study. Gut. Dec. 1995;37(6):830-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8537056].
Bowen DJ, Helmes A, Powers D, et al. Predicting breast cancer screening intentions and behavior with emotion and cognition. J Soc Clin Psychol. Jun. 2003;22(2):213-32. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Boyd NF, Lockwood GA, Martin LJ, et al. Mammographic densities and risk of breast cancer among subjects with a family history of this disease. J Natl Cancer Inst. Aug. 18. 1999;91(16):1404-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10451446].
Brain K, Norman P, Gray J, et al. Anxiety and adherence to breast self-examination in women with a family history of breast cancer. Psychosom Med. Mar. 1999;61(2):181-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10204971].
Brain K, Henderson BJ, Tyndel S, et al. Predictors of breast cancer-related distress following mammography screening in younger women on a family history breast screening programme. Psychooncology. Dec. 2008;17(12):1180-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18506670].
Braithwaite D, Sutton S, Smithson WH, et al. Internet-based risk assessment and decision support for the management of familial cancer in primary care: a survey of GPs' attitudes and intentions. Fam Pract. Dec. 2002;19(6):587-90. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12429659].
Brandt A, Bermejo JL, Sundquist J, et al. Age of onset in familial cancer. Ann Oncol. 2008;19(12):2084-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18653701].
Bratt O, Kristoffersson U, Lundgren R, et al. Sons of men with prostate cancer: Their attitudes regarding possible inheritance of prostate cancer, screening, and genetic testing. Urology. 1997;50(3):360-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9301698].
Bratt O, Kristoffersson U, Lundgren R, et al. Familial and hereditary prostate cancer in southern Sweden. A population-based case-control study. Eur J Cancer. Feb. 1999;35(2):272-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10448270].
Bravi F, Bosetti C, Negri E, et al. Family history of cancer provided by hospital controls was satisfactorily reliable. J Clin Epidemiol. Feb. 2007;60(2):171-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17208123].
Brawley A, Silverman B, Kearney S, et al. Allergic rhinitis in children with attention-deficit/hyperactivity disorder. Ann AllergyAsthma Immunol. 2004;92(6):663-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Brinton LA, Richesson DA, Gierach GL, et al. Prospective evaluation of risk factors for male breast cancer. J Natl Cancer Inst. 2008;100(20):1477-81. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18840816].
Bromen K, Pohlabeln H, Jahn I, et al. Aggregation of lung cancer in families: results from a population-based case-control study in Germany. Am J Epidemiol. Sep. 15. 2000;152(6):497-505. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10997539].
Brown DW, Giles WH, Burke W, et al. Familial aggregation of early-onset myocardial infarction. Community Genet. 2002;5(4):232-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14960877].
Brown N, Naman P, Homel P, et al. Assessment of preventive health knowledge and behaviors of African-American and Afro-Caribbean women in urban settings. J Natl Med Assoc. 2006;98(10):1644-51. Excluded because no eligible outcomes presented. [pmid: 17052056].
Brown SR, Finan PJ, Bishop DT. Are relatives of patients with multiple HNPCC spectrum tumours at increased risk of cancer?. Gut. Nov. 1998;43(5):664-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9824348].
Brownson RC, Alavanja MC, Caporaso N, et al. Family history of cancer and risk of lung cancer in lifetime non-smokers and long-term ex-smokers. Int J Epidemiol. Apr. 1997;26(2):256-63. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9169159].
Brugge D, Lee AC, Woodin M, et al. Native and foreign born as predictors of pediatric asthma in an Asian immigrant population: A cross sectional survey. Environ Health. 2007;6:13. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17474985].
Bruno M, Tommasi S, Stea B, et al. Awareness of breast cancer genetics and interest in predictive genetic testing: A survey of a southern Italian population. Ann Oncol. 2004;15(Suppl 1):i48-i54. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15280188].
Buccheri G, Ferrigno D. Familial and personal history of cancer in bronchogenic carcinoma--frequency and clinical implications. Acta Oncol. 2004;43(1):65-72. Excluded because not an eligible study design. [pmid: 15068322].
Bucholz KK, Nurnberger J, Kramer JR, et al. Comparison of psychiatric diagnoses from interview reports with those from best-estimate procedures. J Stud Alcohol. 2006;67(1):157-68. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16536140].
Bunn JY, Bosompra K, Ashikaga T, et al. Factors influencing intention to obtain a genetic test for colon cancer risk: A population-based study. Prev Med. 2002;34(6):567-77. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12052015].
Burke JP, Williams K, Narayan KMV, et al. A population perspective on diabetes prevention: whom should we target for preventing weight gain?. Diabetes Care. Jul. 2003;26(7):1999-2004. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12832302].
Burke V, Beilin LJ, Dunbar D. Tracking of blood pressure in Australian children. J Hypertens. 2001;19(7):1185-92. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11446707].
Burke W, Culver JO, Bowen D, et al. Genetic counseling for women with an intermediate family history of breast cancer. Am J Med Genet. Feb. 28. 2000;90(5):361-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10706356].
Byrne GJ, Bundred NJ. Does the evidence justify national funding of breast cancer family history clinics?. Breast. 1997;6(6):388-93. Excluded because not an eligible study design.
Cabrinety N, Pisonero MJ, Ajram J, et al. Lipoprotein (a) in obese children with a family history of cardiovascular disease. J Pediatr Endocrinol. Jan. 2002;15(1):77-80. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Caicoya M, Corrales C, Rodriguez T. Family history and stroke: a community case-control study in Asturias, Spain. J Epidemiol Biostat. 1999;4(4):313-20. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10764245].
Calbi M, Giacchetti L, Coppola A, et al. Basophil count in neonates is not suitable for atopy predictivity. J Investig Allergol Clin Immunol. 1996;6(6):383-7. Excluded because no eligible outcomes presented.
Calderon-Garciduenas AL, Paras-Barrientos FU, Cardenas-Ibarra L, et al. Risk factors of breast cancer in Mexican women. Salud Publica Mex. Jan. 2000;42(1):26-33. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10743396].
Callejas JM, Manasanch J, Abad R, et al. Epidemiology of chronic venous insufficiency of the lower limbs in the primary care setting. Int Angiol. 2004;23(2):154-63. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15507894].
Calvocoressi L, Kasl SV, Lee CH, et al. A prospective study of perceived susceptibility to breast cancer and nonadherence to mammography screening guidelines in African American and White women ages 40 to 79 years. Cancer Epidemiol Biomarkers Prev. 2004;13(12):2096-105. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15598767].
Cameron LD, Petrie KJ, Ellis C, et al. Symptom experiences, symptom attributions, and causal attributions in patients following first-time myocardial infarction. International J. 2005;12(1):30-8. Excluded because no eligible outcomes presented.
Cameron LD, Reeve J. Risk perceptions, worry, and attitudes about genetic testing for breast cancer susceptibility. Psychol Health. Apr. 2006;21(2):211-30. Excluded because no eligible outcomes presented.
Camp NJ, Slattery ML. Classification tree analysis: a statistical tool to investigate risk factor interactions with an example for colon cancer (United States). Cancer Causes Control. Nov. 2002;13(9):813-23. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12462546].
Campbell PT, Cotterchio M, Dicks E, et al. Excess body weight and colorectal cancer risk in Canada: Associations in subgroups of clinically defined familial risk of cancer. Cancer Epidemiol Biomarkers Prev. 2007;16(9):1735-44. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17855691].
Canani LH, Gerchman F, Gross JL. Increased familial history of arterial hypertension, coronary heart disease, and renal disease in Brazilian type 2 diabetic patients with diabetic nephropathy. Diabetes Care. Sep. 1998;21(9):1545-50. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9727907].
Canby-Hagino E, Hernandez J, Brand TC, et al. Prostate cancer risk with positive family history, normal prostate examination findings, and PSA less than 4.0 ng/mL. Urology. Oct. 2007;70(4):748-52. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17991549].
Cansu A, Serdaroglu A, Yuksel D, et al. Prevalence of some risk factors in children with epilepsy compared to their controls. Seizure. 2007;16(4):338-44. Excluded because no eligible outcomes presented. [pmid: 17391991].
Cantor SB, Volk RJ, Cass AR, et al. Psychological benefits of prostate cancer screening: The role of reassurance. Health Expect. 2002;5(2):104-13. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12031051].
Cappelli M, Surh L, Humphreys L, et al. Psychological and social determinants of women's decisions to undergo genetic counseling and testing for breast cancer. Clin Genet. 1999;55(6):419-30. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10450858].
Cappelli M, Surh L, Walker M, et al. Psychological and social predictors of decisions about genetic testing for breast cancer in high-risk women. Psychol Health Med. 2001;6(3):321-33. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Caputo S, Capozzi G, Russo MG, et al. Familial recurrence of congenital heart disease in patients with ostium secundum atrial septal defect. Eur Heart J. Oct. 2005;26(20):2179-84. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15980033].
Carney PA, Steiner E, Goodrich ME, et al. Discovery of breast cancers within 1 year of a normal screening mammogram: How are they found?. Ann Fam Med. 2006;4(6):512-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17148629].
Carpenter CL, Ross RK, Paganini-Hill A, et al. Effect of family history, obesity and exercise on breast cancer risk among postmenopausal women. Int J Cancer. Aug. 10. 2003;106(1):96-102. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12794763].
Carpenter S, Broughton M, Marks CG. A screening clinic for relatives of patients with colorectal cancer in a district general hospital. Gut. Jan. 1995;36(1):90-2. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 7890243].
Carr DB, Utzschneider KM, Hull RL, et al. Gestational diabetes mellitus increases the risk of cardiovascular disease in women with a family history of type 2 diabetes. Diabetes Care. Sep. 2006;29(9):2078-83. Excluded because not an eligible population. [pmid: 16936156].
Caruso A, Vigna C, Maggi G, et al. The withdrawal from oncogenetic counselling and testing for hereditary and familial breast and ovarian cancer. A descriptive study of an Italian sample. J Exp Clin Cancer Res. 2008;27:75. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 19025627].
Casey R, Brennan P, Becker N, et al. Influence of familial cancer history on lymphoid neoplasms risk validated in the large European case-control study epilymph. Eur J Cancer. Oct. 2006;42(15):2570-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16928444].
Cassidy A, Myles JP, Duffy SW, et al. Family history and risk of lung cancer: age-at-diagnosis in cases and first-degree relatives. Br J Cancer. Nov. 6. 2006;95(9):1288-90. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17003779].
Ceballos RM, Newcomb PA, Beasley JM, et al. Colorectal cancer cases and relatives of cases indicate similar willingness to receive and disclose genetic information. Genet Test. Sep. 2008;12(3):415-20. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18752450].
Ceber E, Sogukpinar N, Mermer G, et al. Nutrition, lifestyle, and breast cancer risk among Turkish women. Nutr Cancer. 2005;53(2):152-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16573376].
Cerhan JR, Grabrick DM, Vierkant RA, et al. Interaction of adolescent anthropometric characteristics and family history on breast cancer risk in a historical cohort study of 426 families (USA). Cancer Causes Control. 2004;15(1):1-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14970729].
Chambers EC, Tull ES, Fraser H, et al. A family history of diabetes is related to abnormal insulin sensitivity in African-Caribbean girls of low birth weight: Is catch-up weight important?. Ethn Dis. 2005;15(3):424-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16108302].
Chan-Yeung M, Koo LC, Ho JCM, et al. Risk factors associated with lung cancer in Hong Kong. Lung Cancer. 2003;40(2):131-40. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12711113].
Chan-Yeung M, Hegele RG, Dimich-Ward H, et al. Early environmental determinants of asthma risk in a high-risk birth cohort. Pediatr Allergy Immunol. 2008;19(6):482-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18266835].
Chan JA, Meyerhardt JA, Niedzwiecki D, et al. Association of family history with cancer recurrence and survival among patients with stage III colon cancer. JAMA. 2008;299(21):2515-23. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18523220].
Chang-Claude J, Eby N, Kiechle M, et al. Breastfeeding and breast cancer risk by age 50 among women in Germany. Cancer Causes Control. 2000;11(8):687-95. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11065005].
Chang WT, Sun HL, Lue KH, et al. Predictability of early onset atopic dermatitis by cord blood IgE and parental history. Acta Paediatrica Taiwanica. Sep. 2005;46(5):272-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16640000].
Chart PL, Franssen E. Management of women at increased risk for breast cancer: Preliminary results from a new program. Can Med Assoc J. 1997;157(9):1235-42. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9361645].
Chaturvedi V, Reddy KS, Prabhakaran D, et al. Development of a clinical risk score in predicting undiagnosed diabetes in urban Asian Indian adults: a population-based study. CVD Prevention and Control. 2008;3(3):141-51. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Chen J, Millar WJ. Heart disease, family history and physical activity. Health Rep. Aug. 2001;12(4):23-32. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Chen K-T, Chen C-J, Gregg EW, et al. Prevalence of type 2 diabetes mellitus in Taiwan: Ethnic variation and risk factors. Diabetes Res Clin Pract. 2001;51(1):59-66. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11137183].
Chhabra SK, Gupta CK, Chhabra P, et al. Risk factors for development of bronchial asthma in children in Delhi. Ann Allergy Asthma Immunol. Nov. 1999;83(5):385-90. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10582718].
Choi HK, De Vera MA, Krishnan E. Gout and the risk of type 2 diabetes among men with a high cardiovascular risk profile. Rheumatology (Oxford). 2008;47(10):1567-70. Excluded because no eligible outcomes presented. [pmid: 18710901].
Choi SH, Yoo Y, Yu J, et al. Bronchial hyperresponsiveness in young children with allergic rhinitis and its risk factors. Allergy. 2007;62(9):1051-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17686108].
Choo KE, Lau KB, Davis WA, et al. Cardiovascular risk factors in pre-pubertal Malays: effects of diabetic parentage. Diabetes Res Clin Pract. Apr. 2007;76(1):119-25. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16979774].
Chorne-Navia R, Chatterjee N. Prevalence of family history of diabetes in type 2 diabetes patients in Coahuila, Mexico. Hispanic Health Care Int. 2008;6(1):5-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Christiaans I, Birnie E, Bonsel GJ, et al. Uptake of genetic counselling and predictive DNA testing in hypertrophic cardiomyopathy. Eur J Hum Genet. Oct. 2008;16(10):1201-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18478037].
Christie GL, McDougall CM, Helms PJ. Is the increase in asthma prevalence occurring in children without a family history of atopy?. Scott Med J. Dec. 1998;43(6):180-2. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9924756].
Chun J, El Tamer M, Joseph K-A, et al. Predictors of breast cancer development in a high-risk population. Am J Surg. 2006;192(4):474-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16978952].
Church J, McGannon E. Family history of colorectal cancer: how often and how accurately is it recorded?. Dis Colon Rectum. Nov. 2000;43(11):1540-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11089589].
Church JM. A scoring system for the strength of a family history of colorectal cancer. Dis Colon Rectum. May. 2005;48(5):889-96. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15785893].
Ciruzzi M, Schargrodsky H, Rozlosnik J, et al. Frequency of family history of acute myocardial infarction in patients with acute myocardial infarction. Argentine FRICAS (Factores de Riesgo Coronario en America del Sur) Investigators. Am J Cardiol. Jul. 15. 1997;80(2):122-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9230145].
Ciruzzi M, Schargrodsky H, Pramparo P, et al. Attributable risks for acute myocardial infarction in four countries of Latin America. Medicina (Mex). 2003;63(6):697-703. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Clarkson P, Celermajer DS, Powe AJ, et al. Endothelium-dependent dilatation is impaired in young healthy subjects with a family history of premature coronary disease. Circulation. Nov. 18. 1997;96(10):3378-83. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9396430].
Claus EB, Schildkraut JM, Thompson WD, et al. The genetic attributable risk of breast and ovarian cancer. Cancer. Jun. 1. 1996;77(11):2318-24. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8635102].
Claus EB, Stowe M, Carter D. Family history of breast and ovarian cancer and the risk of breast carcinoma in situ. Breast Cancer Res Treat. Mar. 2003;78(1):7-15. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12611452].
Clausen TD, Mathiesen ER, Hansen T, et al. High prevalence of type 2 diabetes and pre-diabetes in adult offspring of women with gestational diabetes mellitus or type 1 diabetes: the role of intrauterine hyperglycemia. Diabetes Care. Feb. 2008;31(2):340-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18000174].
Clavel-Chapelon F, Joseph R, Goulard H. Surveillance behavior of women with a reported family history of colorectal cancer. Prev Med. Feb. 1999;28(2):174-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10048109].
Coady MA, Davies RR, Roberts M, et al. Familial patterns of thoracic aortic aneurysms. Arch Surg. Apr. 1999;134(4):361-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10199307].
Cobbe SM. Baseline risk factors and their association with outcome in the West of Scotland Coronary Prevention Study. Am J Cardiol. 1997;79(6):756-62. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9070554].
Cohen M. Breast canceer early detection, health beliefs, and cancer worries in randomly selected women with and without a family history of breast cancer. Psychooncology. 2006;15(10):873-83. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16374894].
Cohn WF, Ropka ME, Jones SM, et al. Information needs about hereditary breast cancer among women with early-onset breast cancer. Cancer Detect Prev J. 2003;27(5):345-52. Excluded because no eligible outcomes presented.
Colditz GA, Rosner BA, Speizer FE. Risk factors for breast cancer according to family history of breast cancer. For the Nurses' Health Study Research Group. J Natl Cancer Inst. Mar. 20. 1996;88(6):365-71. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8609646].
Cole JC, Ownby DR, Havstad SL, et al. Family history, dust mite exposure in early childhood, and risk for pediatric atopy and asthma. J Allergy Clin Immunol. Jul. 2004;114(1):105-10. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15241351].
Collins LC, Baer HJ, Tamimi RM, et al. The influence of family history on breast cancer risk in women with biopsy-confirmed benign breast disease: results from the Nurses' Health Study. Cancer. Sep. 15. 2006;107(6):1240-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16902983].
Cook D, Crowther M, Meade M, et al. Deep venous thrombosis in medical-surgical critically ill patients: Prevalence, incidence, and risk factors. Crit Care Med. 2005;33(7):1565-71. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16003063].
Cook LS, White JL, Stuart GCE, et al. The reliability of telephone interviews compared with in-person interviews using memory aids. Ann Epidemiol. 2003;13(7):495-501. Excluded because no eligible outcomes presented. [pmid: 12932624].
Cooper GS, Wither J, McKenzie T, et al. The prevalence and accuracy of self-reported history of 11 autoimmune diseases. J Rheumatol. Oct. 2008;35(10):2001-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18785310].
Coppens M, Reijnders JH, Middeldorp S, et al. Testing for inherited thrombophilia does not reduce the recurrence of venous thrombosis. J Thromb Haemost. Sep. 2008;6(9):1474-7. Excluded because no eligible outcomes presented. [pmid: 18540999].
Cormier L, Reid K, Kwan L, et al. Screening behavior in brothers and sons of men with prostate cancer. J Urol. May. 2003;169(5):1715-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12686816].
Correa H, Campi-Azevedo AC, De Marco L, et al. Familial suicide behaviour: Association with probands suicide attempt characteristics and 5-HTTLPR polymorphism. Acta Psychiatr Scand. 2004;110(6):459-64. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15521831].
Cosmi B, Legnani C, Bernardi F, et al. Value of family history in identifying women at risk of venous thromboembolism during oral contraception: observational study. Br Med J. Apr. 28. 2001;322(7293):1024-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11325765].
Cosmi B, Legnani C, Bernardi F, et al. Role of family history in identifying women with thrombophilia and higher risk of venous thromboembolism during oral contraception.[erratum appears in Arch Intern Med. 2003 Aug 11–25;163(15):1778]. Arch Intern Med. May. 12. 2003;163(9):1105-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12742811].
Costa A, Rios M, Casamitjana R, et al. High prevalence of abnormal glucose tolerance and metabolic disturbances in first degree relatives of NIDDM patients. A study in Catalonia, a mediterranean community. Diabetes Res Clin Pract. 1998;41(3):191-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9829348].
Costanza ME, Luckmann R, Stoddard AM, et al. Applying a stage model of behavior change to colon cancer screening. Prev Med. 2005;41(3–4):707-19. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16171854].
Cote ML, Kardia SL, Wenzlaff AS, et al. Risk of lung cancer among white and black relatives of individuals with early-onset lung cancer. JAMA. Jun. 22. 2005;293(24):3036-42. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15972566].
Cotter MP, Gern RW, Ho GY, et al. Role of family history and ethnicity on the mode and age of prostate cancer presentation. Prostate. Mar. 1. 2002;50(4):216-21. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11870799].
Cotterchio M, McKeown-Eyssen G, Sutherland H, et al. Ontario familial colon cancer registry: methods and first-year response rates. Chronic Dis Can. 2000;21(2):81-6. Excluded because no eligible outcomes presented. [pmid: 11007659].
Cottet V, Pariente A, Nalet B, et al. Low compliance with colonoscopic screening in first-degree relatives of patients with large adenomas. Aliment Pharmacol Ther. Jul. 1. 2006;24(1):101-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16803608].
Cottet V, Pariente A, Nalet B, et al. Colonoscopic screening of first-degree relatives of patients with large adenomas: increased risk of colorectal tumors. Gastroenterology. Oct. 2007;133(4):1086-92. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17919484].
Couto E, Hemminki K. Estimates of heritable and environmental components of familial breast cancer using family history information. Br J Cancer. Jun. 4. 2007;96(11):1740-2. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17473828].
Couto E, Banks E, Reeves G, et al. Family history and breast cancer tumour characteristics in screened women. Int J Cancer. Dec. 15. 2008;123(12):2950-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18816631].
Covelli MM. The relationship of blood pressure and cortisol reactivity to family history of hypertension of African American adolescents. J Cardiovasc Nurs. Sep. 2006;21(5):347-53. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16966911].
Cowan R, Meiser B, Giles GG, et al. The beliefs, and reported and intended behaviors of unaffected men in response to their family history of prostate cancer. Genet Med. Jun. 2008;10(6):430-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18496220].
Cox B, Sneyd MJ, Paul C, et al. Risk factors for prostate cancer: A national case-control study. Int J Cancer. Oct. 1. 2006;119(7):1690-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16646073].
Cox GF, Sleeper LA, Lowe AM, et al. Factors associated with establishing a causal diagnosis for children with cardiomyopathy. Pediatrics. Oct. 2006;118(4):1519-31. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17015543].
Crepeau AZ, Willoughby L, Pinsky B, et al. Accuracy of personal breast cancer risk estimation in cancer-free women during primary care visits. Women Health. 2008;47(2):113-30. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18681103].
Crest AB, Aiello EJ, Anderson ML, et al. Varying levels of family history of breast cancer in relation to mammographic breast density (United States). Cancer Causes Control. Aug. 2006;17(6):843-50. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16783612].
Criqui MH, Denenberg JO, Bergan J, et al. Risk factors for chronic venous disease: The San Diego Population Study. J Vasc Surg. 2007;46(2):331-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17600666].
Crispim D, Canani LH, Gross JL, et al. Familial history of type 2 diabetes in patients from Southern Brazil and its influence on the clinical characteristics of this disease. Arq Bras Endocrinol Metabol. Oct. 2006;50(5):862-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17160209].
Crispo A, D'Aiuto G, De Marco M, et al. Gail model risk factors: impact of adding an extended family history for breast cancer. Breast J. May. 2008;14(3):221-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18373641].
Cui HB, Wang SH, Wang DQ, et al. Modified classic risk factors for coronary artery disease in Chinese Han population. Chin Med Sci J. 2007;22(4):216-23. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18246668].
Cui J, Staples MP, Hopper JL, et al. Segregation analyses of 1,476 population-based Australian families affected by prostate cancer. Am J Hum Genet. May. 2001;68(5):1207-18. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11309686].
Cuijpers P, Smit F, Willemse G. Predicting the onset of major depression in subjects with subthreshold depression in primary care: A prospective study. Acta Psychiatr Scand. 2005;111(2):133-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15667432].
Cull A, Fry A, Rush R, et al. Cancer risk perceptions and distress among women attending a familial ovarian cancer clinic. Br J Cancer. Mar. 2. 2001;84(5):594-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11237377].
Cummings SR, Lee JS, Lui LY, et al. Sex hormones, risk factors, and risk of estrogen receptor-positive breast cancer in older women: A long-term prospective study. Cancer Epidemiol Biomarkers Prev. 2005;14(5):1047-51. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15894651].
D'Avanzo B, La Vecchia C. Risk factors for male breast cancer. Br J Cancer. 1995;71(6):1359-62. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 7779739].
Dalal I, Binson I, Reifen R, et al. Food allergy is a matter of geography after all: Sesame as a major cause of severe IgE-mediated food allergic reactions among infants and young children in Israel. Allergy. 2002;57(4):362-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11906370].
Dallongeville J, Grupposo MC, Cottel D, et al. Association between the metabolic syndrome and parental history of premature cardiovascular disease. Eur Heart J. Mar. 2006;27(6):722-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16401673].
Damber L, Gronberg H, Damber J-E. Familial prostate cancer and possible associated malignancies: Nation- wide register cohort study in Sweden. Int J Cancer. 1998;78(3):293-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9766560].
Damci T, Osar Z, Ilkova H. Higher blood pressure in normoalbuminuric type 1 diabetic patients with a familial history of type 2 diabetes. Diabetes Metab. Nov. 2002;28(5):417-20. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12461481].
Davey RX, Hamblin PS. Selective versus universal screening for gestational diabetes mellitus: an evaluation of predictive risk factors. Med J Aust. Feb. 5. 2001;174(3):118-21. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11247613].
Davids SL, Schapira MM, McAuliffe TL, et al. Predictors of pessimistic breast cancer risk perceptions in a primary care population. J Gen Intern Med. Apr. 2004;19(4):310-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15061739].
Davis LL, Frazier EC, Gaynes BN, et al. Are depressed outpatients with and without a family history of substance use disorder different? A baseline analysis of the STAR*D cohort. J Clin Psychiatry. Dec. 2007;68(12):1931-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18162025].
Davis S, Stewart S, Bloom J. Increasing the accuracy of perceived breast cancer risk: Results from a randomized trial with Cancer Information Service callers. Prev Medicine. Jul. 2004;39(1):64-73. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Davis TME, Pramukkul P, Suputtamongkol Y, et al. Glucose tolerance in rural diabetic Thais, first-degree relatives and non-diabetic controls. Diabetes Res Clin Pract. 1995;27(3):171-80. Excluded because no eligible outcomes presented. [pmid: 7555598].
Dawson DA, Grant BF. Family history of alcoholism and gender: Their combined effects on DSM- IV alcohol dependence and major depression. J Stud Alcohol. 1997;59(1):97-106. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
De Bacquer D, De Backer G, Kornitzer M, et al. Parental history of premature coronary heart disease mortality and signs of ischemia on the resting electrocardiogram. J Am Coll Cardiol. May. 1999;33(6):1491-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10334413].
de Bock GH, Jacobi CE, Seynaeve C, et al. A family history of breast cancer will not predict female early onset breast cancer in a population-based setting. BMC Cancer. 2008;8:203. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18651949].
de Jong AE, Vasen HF. The frequency of a positive family history for colorectal cancer: a population-based study in the Netherlands. Neth J Med. Nov. 2006;64(10):367-70. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17122453].
de Jongh S, Lilien MR, Bakker HD, et al. Family history of cardiovascular events and endothelial dysfunction in children with familial hypercholesterolemia. Atherosclerosis. Jul. 2002;163(1):193-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12048139].
De Oliveira MS, Serra E Silva, Papoila AL, et al. Assessment of global cardiovascular risk and risk factors in Portugal according to the SCORE model. J Public Health. 2008;16(5):361-7. Excluded because no eligible outcomes presented.
De Sario M, Di Domenicantonio R, Corbo G, et al. Characteristics of early transient, persistent, and late onset wheezers at 9 to 11 years of age. J Asthma. Oct. 2006;43(8):633-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17050231].
De Simone M, Verrotti A, Cappa M, et al. Lipoprotein (a) in childhood: correlations with family history of cardiovascular disease. J Endocrinol Invest. May. 2003;26(5):414-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12906368].
De Sutter J, De Bacquer D, Kotseva K, et al. Screening of family members of patients with premature coronary heart disease; results from the EUROASPIRE II family survey. Eur Heart J. Feb. 2003;24(3):249-57. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12590902].
DeFaria YD, Freeman MW, Meigs JB, et al. Risk Factors for Coronary Artery Disease in Patients With Elevated High-Density Lipoprotein Cholesterol. Am J Cardiol. 2007;99(1):1-4. Excluded because no eligible outcomes presented. [pmid: 17196452].
Degli EE, Di Martino M, Sturani A, et al. Risk factors for uncontrolled hypertension in Italy. J Hum Hypertens. 2004;18(3):207-13. Excluded because family history not collected. [pmid: 14973516].
Dehlink E, Prandstetter C, Eiwegger T, et al. Increased prevalence of latex-sensitization among children with chronic renal failure. Allergy. 2004;59(7):734-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15180760].
Dekker LRC, Bezzina CR, Henriques JPS, et al. Familial sudden death is an important risk factor for primary ventricular fibrillation: A case-control study in acute myocardial infarction patients. Circulation. 2006;114(11):1140-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16940195].
DelBello MP, Carlson GA, Tohen M, et al. Rates and Predictors of Developing a Manic or Hypomanic Episode 1 to 2 Years Following a First Hospitalization for Major Depression with Psychotic Features. J Child Adolesc Psychopharmacol. 2003;13(2):173-85. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12880511].
Delpisheh A, Kelly Y, Rizwan S, et al. Salivary cotinine, doctor-diagnosed asthma and respiratory symptoms in primary schoolchildren. Matern Child Health J. Mar. 2008;12(2):188-93. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17557199].
Deo SS, Gore SD, Deobagkar DN, et al. Study of inheritance of diabetes mellitus in Western Indian population by pedigree analysis. J Assoc Physicians India. Jun. 2006;54:441-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16909690].
Derinoz O, Tumer L, Hasanoglu A, et al. Cholesterol screening in school children: is family history reliable to choose the ones to screen?. Acta Paediatr. Dec. 2007;96(12):1794-8. Excluded because no eligible outcomes presented. [pmid: 17971187].
Devi G, Marder K, Schofield PW, et al. Validity of family history for the diagnosis of dementia among siblings of patients with late-onset Alzheimer's disease. Genet Epidemiol. 1998;15(3):215-23. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9593109].
Deyanov C, Vangelova K. Blood pressure response to exercise test and serum lipids in normotensive men with positive family history of hypertension. Cent Eur J Public Health. Dec. 2006;14(4):186-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17243498].
Dezateux C, Stocks J, Dundas I, et al. Impaired airway function and wheezing in infancy: The influence of maternal smoking and a genetic predisposition to asthma. Am J Respir Crit Care Med. 1999;159(2):403-10. Excluded because no eligible outcomes presented. [pmid: 9927350].
Di Cianni G, Volpe L, Lencioni C, et al. Prevalence and risk factors for gestational diabetes assessed by universal screening. Diabetes Res Clin Pract. 2003;62(2):131-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14581150].
Dietrich JE, Hertweck SP, Perlman SE. Efficacy of family history in determining thrombophilia risk. J Pediatr Adolesc Gynecol. Aug. 2007;20(4):221-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17673133].
Dilsaver SC, Akiskal HS, Akiskal KK, et al. Dose-response relationship between number of comorbid anxiety disorders in adolescent bipolar/unipolar disorders, and psychosis, suicidality, substance abuse and familiality. J Affect Disord. 2006;96(3):249-58. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16904187].
Dominguez FJ, Jones JL, Zabicki K, et al. Prevalence of hereditary breast/ovarian carcinoma risk in patients with a personal history of breast or ovarian carcinoma in a mammography population. Cancer. Nov. 1. 2005;104(9):1849-53. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16136597].
Dominguez FJ, Lawrence C, Halpern EF, et al. Accuracy of self-reported personal history of cancer in an outpatient breast center. J Genet Couns. Jun. 2007;16(3):341-5. Excluded because family history not collected. [pmid: 17508275].
Dong C, Hemminki K. Multiple primary cancers of the colon, breast and skin (melanoma) as models for polygenic cancers. Int J Cancer. Jun. 15. 2001;92(6):883-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11351311].
Dong C, Hemminki K. Modification of cancer risks in offspring by sibling and parental cancers from 2,112,616 nuclear families. Int J Cancer. Apr. 1. 2001;92(1):144-50. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11279618].
Doughty M, Mehta R, Bruckman D, et al. Acute myocardial infarction in the young - The University of Michigan experience. Am Heart J. 2002;143(1):56-62. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11773912].
Douglas FS, O'Dair LC, Robinson M, et al. The accuracy of diagnoses as reported in families with cancer: a retrospective study. J Med Genet. Apr. 1999;36(4):309-12. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10227399].
Dove-Edwin I, Sasieni P, Adams J, et al. Prevention of colorectal cancer by colonoscopic surveillance in individuals with a family history of colorectal cancer: 16 Year, prospective, follow-up study. Br Med J. 2005;331(7524):1047-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16243849].
Drake BF, Lathan CS, Okechukwu CA, et al. Racial differences in prostate cancer screening by family history. Ann Epidemiol. Jul. 2008;18(7):579-83. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18486487].
Drescher C, Holt SK, Andersen MR, et al. Reported ovarian cancer screening among a population-based sample in Washington State. Obstet Gynecol. 2000;96(1):70-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10862845].
Drossaert CC, Boer H, Seydel ER. Perceived risk, anxiety, mammogram uptake, and breast self-examination of women with a family history of breast cancer: the role of knowing to be at increased risk. Cancer Detect Prev. 1996;20(1):76-85. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8907207].
Du Rocher Schudlich TD, Youngstrom EA, Calabrese JR, et al. The role of family functioning in bipolar disorder in families. J Abnorm Child Psychol. 2008;36(6):849-63. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18270810].
Duijm LEM, Guit GL, Zaat JOM. Mammographic surveillance of asymptomatic breast cancer relatives in general practice: rate of re-attendance and GP- and patient-related barriers. Fam Pract. 1997;14(6):450-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9476075].
Dyck R, Klomp H, Tan LK, et al. A comparison of rates, risk factors, and outcomes of gestational diabetes between aboriginal and non-aboriginal women in the Saskatoon Health District. Diabetes Care. 2002;25(3):487-93. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11874935].
Easton DF, Matthews FE, Ford D, et al. Cancer mortality in relatives of women with ovarian cancer: the OPCS Study. Office of Population Censuses and Surveys. Int J Cancer. Jan. 26. 1996;65(3):284-94. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8575846].
Eaton CB, Bostom AG, Yanek L, et al. Family history and premature coronary heart disease. J Am Board Fam Pract. Sep. 1996;9(5):312-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8884668].
Egan KM, Stampfer MJ, Rosner BA, et al. Risk factors for breast cancer in women with a breast cancer family history. Cancer Epidemiol Biomarkers Prev. May. 1998;7(5):359-64. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9610783].
Egawa N, Tu Y, Sanaka M, et al. Family history of diabetes and pancreatic cancer. Pancreas. Jan. 2005;30(1):15-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15632694].
Ehlermann P, Weichenhan D, Zehelein J, et al. Adverse events in families with hypertrophic or dilated cardiomyopathy and mutations in the MYBPC3 gene. BMC Med Genet. 2008;9:95. Excluded because family history not collected. [pmid: 18957093].
Ehrmann DA, Kasza K, Azziz R, et al. Effects of race and family history of type 2 diabetes on metabolic status of women with polycystic ovary syndrome. J Clin Endocrinol Metab. Jan. 2005;90(1):66-71. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15507516].
Eisenmann JC, Wrede J, Heelan KA. Associations between adiposity, family history of CHD and blood pressure in 3–8 year-old children. J Hum Hypertens. Sep. 2005;19(9):675-81. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15905885].
Ekerljung L, Ronmark E, Larsson K, et al. No further increase of incidence of asthma: Incidence, remission and relapse of adult asthma in Sweden. Respir Med. 2008;102(12):1730-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18760582].
Elbagir MN, Eltom MA, Elmahadi EMA, et al. A high prevalence of diabetes mellitus and impaired glucose tolerance in the Danagla community in Northern Sudan. Diabet Med. 1998;15(2):164-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9507920].
Eldon BJ, Jonsson E, Tomasson J, et al. Familial risk of prostate cancer in Iceland. BJU Int. Dec. 2003;92(9):915-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14632846].
Elis A, Pereg D, Tirosh A, et al. Family history of cardiovascular disease does not predict risk-reducing behavior. Eur J Cardiovasc Prev Rehabil. Jun. 2008;15(3):325-8. Excluded because no eligible outcomes presented. [pmid: 18525388].
Elit L, Esplen MJ, Butler K, et al. Quality of life and psychosexual adjustment after prophylactic oophorectomy for a family history of ovarian cancer. Fam Cancer. 2001;1(3–4):149-56. Excluded because family history not collected. [pmid: 14574171].
Emery J, Morris H, Goodchild R, et al. The GRAIDS Trial: a cluster randomised controlled trial of computer decision support for the management of familial cancer risk in primary care. Br J Cancer. Aug. 20. 2007;97(4):486-93. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17700548].
Englert H, Small-McMahon J, Chambers P, et al. Familial risk estimation in systemic sclerosis. Aust N Z J Med. Feb. 1999;29(1):36-41. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10200811].
Erasmus RT, Blanco BE, Okesina AB, et al. Importance of family history in type 2 black South African diabetic patients. Postgrad Med J. May. 2001;77(907):323-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11320276].
Erbey JR, Kuller LH, Becker DJ, et al. The association between a family history of type 2 diabetes and coronary artery disease in a type 1 diabetes population. Diabetes Care. Apr. 1998;21(4):610-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9571351].
Erblich J, Bovbjerg DH, Valdimarsdottir HB. Looking forward and back: distress among women at familial risk for breast cancer. Ann Behav Med. 2000;22(1):53-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10892528].
Erblich J, Bovbjerg DH, Norman C, et al. It won't happen to me: lower perception of heart disease risk among women with family histories of breast cancer. Prev Med. Dec. 2000;31(6):714-21. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11133339].
Etchegoyen GS, Ortiz D, Goya RG, et al. Assessment of cardiovascular risk factors in menopausal Argentinian women. Gerontology. 1995;41(3):166-72. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 7601369].
Etzel CJ, Amos CI, Spitz MR. Risk for smoking-related cancer among relatives of lung cancer patients. Cancer Res. Dec. 1. 2003;63(23):8531-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14679021].
Evans DG, Walsh S, Jeacock J, et al. Incidence of hereditary non-polyposis colorectal cancer in a population-based study of 1137 consecutive cases of colorectal cancer. Br J Surg. Sep. 1997;84(9):1281-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9313714].
Evans M, Palta M, Sadek M, et al. Associations between family history of asthma, bronchopulmonary dysplasia, and childhood asthma in very low birth weight children. Am J Epidemiol. Sep. 1. 1998;148(5):460-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9737558].
Ewertz M, Holmberg L, Tretli S, et al. Risk factors for male breast cancer--a case-control study from Scandinavia. Acta Oncol. 2001;40(4):467-71. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11504305].
Faheem M, Khurram M, Jafri IA, et al. Risk factors for breast cancer in patients treated at NORI Hospital, Islamabad. J Pak Med Assoc. 2007;57(5):242-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17571480].
Fahim S, van Duijn CM, Baker FM, et al. A study of familial aggregation of depression, dementia and Parkinson's disease. Eur J Epidemiol. Apr. 1998;14(3):233-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9663515].
Fang J, Foo SH, Fung C, et al. Stroke risk among Chinese immigrants in New York City. J Immigr Minor Health. 2006;8(4):387-93. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16732434].
Fedorowski A, Burri P, Hulthen L, et al. The metabolic syndrome and risk of myocardial infarction in familial hypertension (hypertension heredity in Malmo evaluation study). J Hypertens. Jan. 2009;27(1):109-17. Excluded because family history not collected. [pmid: 19050451].
Fernandez-Egea E, Miller B, Bernardo M, et al. Parental history of type 2 diabetes in patients with nonaffective psychosis. Schizophr Res. Jan. 2008;98(1–3):302-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18031995].
Fernandez E, La Vecchia C, Talamini R, et al. Joint effects of family history and adult life dietary risk factors on colorectal cancer risk. Epidemiology. May. 2002;13(3):360-3. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11964940].
Fernandez E, Gallus S, La Vecchia C, et al. Family history and environmental risk factors for colon cancer. Cancer Epidemiol Biomarkers Prev. Apr. 2004;13(4):658-61. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15066934].
Fernandez E, Gallus S, La Vecchia C, et al. Family history and environmental risk factors for colon cancer. Cancer Epidemiol Biomarkers Prev. 2004;13(4):658-61. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15066934].
Ferrante JM, Ohman-Strickland P, Hahn KA, et al. Self-report versus medical records for assessing cancer-preventive services delivery. Cancer Epidemiol Biomarkers Prev. 2008;17(11):2987-94. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18990740].
Ferrari M, Tardivo S, Zanolin ME, et al. Serious childhood respiratory infections and asthma in adult life. A population based study. Ann Allergy Asthma Immunol. 1999;83(5):391-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10582719].
Fesharakinia A, Kazemi T, Zarban A, et al. Comparison of Lipoprotein (a) and Apolipoproteins in children with and without familial history of premature coronary artery disease. Iran J Pediatr. 2008;18(2):159-62. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Figueiredo JC, Ennis M, Knight JA, et al. Influence of young age at diagnosis and family history of breast or ovarian cancer on breast cancer outcomes in a population-based cohort study. Breast Cancer Res Treat. Sep. 2007;105(1):69-80. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17115108].
Filion E, Taussky D, Bahary JP, et al. Higher frequency of familial clustering of prostate cancer in French-Canadian men. J Urol. 2007;178(4:Pt 1):1265-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17698103].
Finney Rutten LJ, Iannotti RJ. Health beliefs, salience of breast cancer family history, and involvement with breast cancer issues: adherence to annual mammography screening recommendations. Cancer Detect Prev. 2003;27(5):353-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14585322].
Finney LJ, Iannotti RJ. The impact of family history of breast cancer on women's health beliefs, salience of breast cancer family history, and degree of involvement in breast cancer issues. Women Health. 2001;33(3–4):15-28. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11527103].
Fioretti F, Tavani A, Bosetti C, et al. Risk factors for breast cancer in nulliparous women. Br J Cancer. 1999;79(11–12):1923-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10206315].
Fisher TJ, Kirk J, Hopper JL, et al. A simple tool for identifying unaffected women at a moderately increased or potentially high risk of breast cancer based on their family history. Breast. Apr. 2003;12(2):120-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14659341].
Flint EP, Hays JC, Krishnan KRR, et al. Suicidal behaviors in depressed men with a family history of suicide: effects of psychosocial factors and age. Aging Ment Health. Nov. 1998;2(4):286-99. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Flossmann E, Rothwell PM. Family history of stroke in patients with transient ischemic attack in relation to hypertension and other intermediate phenotypes. Stroke. Apr. 2005;36(4):830-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15746455].
Ford BM, Evans JS, Stoffel EM, et al. Factors associated with enrollment in cancer genetics research. Cancer Epidemiol Biomarkers Prev. 2006;15(7):1355-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16835336].
Fornage M, Lopez DS, Roseman JM, et al. Parental history of stroke and myocardial infarction predicts coronary artery calcification: The Coronary Artery Risk Development in Young Adults (CARDIA) study. Eur J Cardiovasc Prev Rehabil. Oct. 2004;11(5):421-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15616417].
Fornasarig M, Campagnutta E, Talamini R, et al. Risk factors for endometrial cancer according to familial susceptibility. Int J Cancer. Jul. 3. 1998;77(1):29-32. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9639390].
Fox ER, Benjamin EJ, Sarpong DF, et al. Epidemiology, heritability, and genetic linkage of C-reactive protein in African Americans (from the Jackson Heart Study). Am J Cardiol. Oct. 1. 2008;102(7):835-41. Excluded because family history not collected. [pmid: 18805107].
Fraser GE, Shavlik D. Risk factors, lifetime risk, and age at onset of breast cancer. Ann Epidemiol. Aug. 1997;7(6):375-82. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9279446].
Freedman AN, Slattery ML, Ballard-Barbash R, et al. Colorectal cancer risk prediction tool for white men and women without known susceptibility. J Clin Oncol. Feb. 10. 2009;27(5):686-93. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 19114701].
Frezzo TM, Rubinstein WS, Dunham D, et al. The genetic family history as a risk assessment tool in internal medicine. Genet Med. 2003;5(2):84-91. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12644777].
Frich JC, Ose L, Malterud K, et al. Perceived vulnerability to heart disease in patients with familial hypercholesterolemia: a qualitative interview study. Ann Fam Med. May. 2006;4(3):198-204. Excluded because not an eligible study design. [pmid: 16735520].
Friedlander Y, Siscovick DS, Weinmann S, et al. Family history as a risk factor for primary cardiac arrest. Circulation. Jan. 20. 1998;97(2):155-60. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9445167].
Friedlander Y, Arbogast P, Schwartz SM, et al. Family history as a risk factor for early onset myocardial infarction in young women. Atherosclerosis. May. 2001;156(1):201-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11369015].
Friedlander Y, Siscovick DS, Arbogast P, et al. Sudden death and myocardial infarction in first degree relatives as predictors of primary cardiac arrest. Atherosclerosis. May. 2002;162(1):211-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11947916].
Friedman LC, Webb JA, Everett TE. Psychosocial and medical predictors of colorectal cancer screening among low-income medical outpatients. J Cancer Educ. 2004;19(3):180-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15458875].
Friedman S. Sharing family history. CURE: Cancer Updates, Research & Education. 2003;2(3):58. Excluded because not an eligible study design.
Fry A, Rush R, Busby-Earle C, et al. Deciding about prophylactic oophorectomy: What is important to women at increased risk of ovarian cancer?. Prev Med. Dec. 2001;33(6):578-85. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11716653].
Fu C-C, Chen J-D, Chern TPS, et al. The relationship between parental medical histories and coronary risk factors in adult progeny of type 2 diabetics. Tzu Chi Medical Journal. 2002;14(1):7-12. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Fuchs CS, Willett WC, Colditz GA, et al. The influence of folate and multivitamin use on the familial risk of colon cancer in women. Cancer Epidemiol Biomarkers Prev. Mar. 2002;11(3):227-34. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11895870].
Fujisawa T, Ikegami H, Kawaguchi Y, et al. Common genetic basis between type 1 and type 2 diabetes mellitus indicated by interview-based assessment of family history. Diabetes Res Clin Pract. Dec. 2004;66(Suppl 1):S91-S915. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15563988].
Fujiwara S, Suyama A, Cologne JB, et al. Prevalence of adult-onset multifactorial disease among offspring of atomic bomb survivors. Radiat Res. Oct. 2008;170(4):451-7. Excluded because family history not collected. [pmid: 19024652].
Fukiwake N, Furusyo N, Takeoka H, et al. Association factors for atopic dermatitis in nursery school children in Ishigaki Islands - Kyushu University Ishigaki atopic dermatitis study (KIDS). Eur J Dermatol. 2008;18(5):571-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18693163].
Gaff CL, Aragona C, MacInnis RJ, et al. Accuracy and completeness in reporting family history of prostate cancer by unaffected men. Urology. Jun. 2004;63(6):1111-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15183962].
Gaga M, Papageorgiou N, Yiourgioti G, et al. Risk factors and characteristics associated with severe and difficult to treat asthma phenotype: An analysis of the ENFUMOSA group of patients based on the ECRHS questionnaire. Clin Exp Allergy. 2005;35(7):954-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16008684].
Gallus S, Foschi R, Talamini R, et al. Risk Factors for Prostate Cancer in Men Aged Less Than 60 Years: A Case-Control Study from Italy. Urology. 2007;70(6):1121-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18158031].
Ganguly SS, Dutta PK, Tilak VW. Evaluation of some risk factors for ischaemic heart disease under a matched pairs case-control design. Indian J Med Res. Jun. 1997;105:278-82. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9277042].
Garbers V, Toniolo PG, Taioli E. Changes in self-reported family history of breast cancer with change in case-control status. Eur J Epidemiol. 2001;17(6):517-20. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11949722].
Garcia K, Eisenmann JC, Bartee RT. Does a family history of coronary heart disease modify the relationship between physical activity and blood pressure in young adults?. Eur J Cardiovasc Prev Rehabil. Jun. 2004;11(3):201-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15179100].
Gazit V, Tasher D, Hanukoglu A, et al. Atopy in children and adolescents with insulin-dependent diabetes mellitus. Isr Med Assoc J. Dec. 2008;10(12):858-61. Excluded because no eligible outcomes presented. [pmid: 19160942].
George S, Berth-Jones J, Graham-Brown RA. A possible explanation for the increased referral of atopic dermatitis from the Asian community in Leicester. Br J Dermatol. Apr. 1997;136(4):494-7. Excluded because no eligible outcomes presented. [pmid: 9155946].
Georgy V, Fahim HI, El Gaafary M, et al. Prevalence and socioeconomic associations of asthma and allergic rhinitis in northern Africa. Eur Respir J. 2006;28(4):756-62. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16737986].
Ghadirian P, Howe GR, Hislop TG, et al. Family history of prostate cancer: a multi-center case-control study in Canada. Int J Cancer. Mar. 17. 1997;70(6):679-81. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9096649].
Ghadirian P, Lacroix A, Perret C, et al. Sociodemographic characteristics, smoking, medical and family history, and breast cancer. Cancer Detect Prev. 1998;22(6):485-94. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9824370].
Gidron Y, Berger R, Lugasi B, et al. Interactions of psychological factors and family history in relation to coronary artery disease. Coron Artery Dis. Jun. 2002;13(4):205-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12193846].
Gil F, Mendez I, Sirgo A, et al. Perception of breast cancer risk and surveillance behaviours of women with family history of breast cancer: a brief report on a Spanish cohort. Psychooncology. Dec. 2003;12(8):821-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14681955].
Gilani GM, Kamal S. Risk factors for breast cancer in Pakistani women aged less than 45 years. Ann Hum Biol. Jul. 2004;31(4):398-407. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15513691].
Gilbar O, Borovik R. How daughters of women with breast cancer cope with the threat of the illness. Behav Med. 1998;24(3):115-21. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9850805].
Gilliam LK, Liese AD, Bloch CA, et al. Family history of diabetes, autoimmunity, and risk factors for cardiovascular disease among children with diabetes in the SEARCH for Diabetes in Youth Study. Pediatr Diabetes. Dec. 2007;8(6):354-61. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18036060].
Gilliland FD, Larson M, Chao A. Risk factor information found in medical records of lung and prostate cancer cases, New Mexico Tumor Registry (United States). Cancer Causes Control. Jul. 1997;8(4):598-604. Excluded because no eligible outcomes presented. [pmid: 9242475].
Gilvarry CM, Sham PC, Jones PB, et al. Family history of autoimmune diseases in psychosis. Schizophr Res. Mar. 1996;19(1):33-40. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9147494].
Glans F, Elgzyri T, Shaat N, et al. Immigrants from the Middle-East have a different form of Type 2 diabetes compared with Swedish patients. Diabet Med. Mar. 2008;25(3):303-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18307458].
Glanz K, Grove J, Le Marchand L, et al. Underreporting of family history of colon cancer: correlates and implications. Cancer Epidemiol Biomarkers Prev. Jul. 1999;8(7):635-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10428202].
Glaser SL, Chang ET, Horning SJ, et al. Understanding the validity of self-reported positive family history of lymphoma in extended families to facilitate genetic epidemiology and clinical practice. Leuk Lymphoma. Jun. 2007;48(6):1110-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17577774].
Glover FE Jr, Coffey DS, Douglas LL, et al. Familial study of prostate cancer in Jamaica. Urology. Sep. 1998;52(3):441-3. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9730457].
Glowinska B, Urban M, Koput A. Cardiovascular risk factors in children with obesity, hypertension and diabetes: lipoprotein(a) levels and body mass index correlate with family history of cardiovascular disease. Eur J Pediatr. Oct. 2002;161(10):511-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12297895].
Glumer C, Carstensen B, Sandbaek A, et al. A Danish Diabetes Risk Scope for Targeted Screening: The Inter99 study. Diabetes Care. 2004;27(3):727-33. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14988293].
Gnanalingham MG, Manns JJ. Patient awareness of genetic and environmental risk factors in non-insulin-dependent diabetes mellitus--relevance to first-degree relatives. Diabet Med. Aug. 1997;14(8):660-2. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9272592].
Godard B, Foulkes WD, Provencher D, et al. Risk factors for familial and sporadic ovarian cancer among French Canadians: a case-control study. Am J Obstet Gynecol. Aug. 1998;179(2):403-10. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9731846].
Gokcel A, Ozsahin AK, Sezgin N, et al. High Prevalence of Diabetes in Adana, a Southern Province of Turkey. Diabetes Care. 2003;26(11):3031-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14578235].
Goldstein IB, Shapiro D, Guthrie D. Ambulatory Blood Pressure and Family History of Hypertension in Healthy Men and Women. Am J Hypertens. 2006;19(5):486-91. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16647620].
Goldstein IB, Shapiro D, Weiss RE. How family history and risk factors for hypertension relate to ambulatory blood pressure in healthy adults. J Hypertens. Feb. 2008;26(2):276-83. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18192842].
Gomez JE, Lantry BR, Saathoff KN. Current use of adequate preparticipation history forms for heart disease screening of high school athletes. Arch Pediatr Adolesc Med. Jul. 1999;153(7):723-6. Excluded because not an eligible population. [pmid: 10401805].
Gong L, Kao WH, Brancati FL, et al. Association between parental history of type 2 diabetes and glycemic control in urban African Americans. Diabetes Care. Sep. 2008;31(9):1773-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18535188].
Gonzalez-Ortiz M, Martinez-Abundis E, Cardona-Munoz EG, et al. Metabolic profile and insulin sensitivity in healthy young Mexicans with a strong family history of non-insulin-dependent diabetes mellitus in the paternal branch. Arch Med Res. 1997;28(3):421-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9291642].
Gonzalez-Ortiz M, Martinez-Abundis E. Maternal effect of Type 2 diabetes mellitus on insulin sensitivity and metabolic profile in healthy young Mexicans. Diabetes Nutr Metab. Feb. 1999;12(1):32-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10517304].
Goodwin RD, Wickramaratne P, Nomura Y, et al. Familial depression and respiratory illness in children. Arch Pediatr Adolesc Med. May. 2007;161(5):487-94. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17485626].
Gorlova OY, Zhang Y, Schabath MB, et al. Never smokers and lung cancer risk: a case-control study of epidemiological factors. Int J Cancer. Apr. 1. 2006;118(7):1798-804. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16217766].
Gorlova OY, Weng SF, Zhang Y, et al. Aggregation of cancer among relatives of never-smoking lung cancer patients. Int J Cancer. Jul. 1. 2007;121(1):111-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17304511].
Grabrick DM, Hartmann LC, Cerhan JR, et al. Risk of breast cancer with oral contraceptive use in women with a family history of breast cancer. JAMA. Oct. 11. 2000;284(14):1791-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11025831].
Gramling R, Anthony D, Lowery J, et al. Association between screening family medical history in general medical care and lower burden of cancer worry among women with a close family history of breast cancer. Genet Med. Nov. 2005;7(9):640-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16301866].
Gramling R, Anthony D, Simmons E, et al. Self-rated breast cancer risk among women reporting a first-degree family history of breast cancer on office screening questionnaires in routine medical care: the role of physician-delivered risk feedback. Genet Med. Oct. 2006;8(10):658-64. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17079883].
Grandi AM, Zanzi P, Broggi R, et al. Longitudinal changes of insulin sensitivity in essential hypertension: Influence of blood pressure control and familial predisposition to hypertension. J Clin Endocrinol Metab. 2001;86(7):3027-31. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11443163].
Granstrom C, Sundquist J, Hemminki K. Population attributable fractions for ovarian cancer in Swedish women by morphological type. Br J Cancer. 2008;98(1):199-205. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18071361].
Grant BF, Dawson DA, Stinson FS, et al. The Alcohol Use Disorder and Associated Disabilities Interview Schedule-IV (AUDADIS-IV): Reliability of alcohol consumption, tobacco use, family history of depression and psychiatric diagnostic modules in a general population sample. Drug Alcohol Depend. 2003;71(1):7-16. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12821201].
Grasbeck A, Horstmann V, Nilsson K, et al. Dementia in first-degree relatives of patients with frontotemporal dementia: a family history study. Dement Geriatr Cogn Disord. 2005;19(2–3):145-53. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15627762].
Grassi M, Bugiani M, De Marco R. Investigating indicators and determinants of asthma in young adults. Eur J Epidemiol. 2006;21(11):831-42. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17119880].
Gravely-Witte S, Stewart DE, Suskin N, et al. Cardiologists' charting varied by risk factor, and was often discordant with patient report. J Clin Epidemiol. 2008;61(10):1073-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18411042].
Greenlund KJ, Valdez R, Bao W, et al. Verification of parental history of coronary artery disease and associations with adult offspring risk factors in a community sample: the Bogalusa Heart Study. Am J Med Sci. Apr. 1997;313(4):220-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9099152].
Greggi S, Parazzini F, Paratore MP, et al. Risk factors for ovarian cancer in central Italy. Gynecol Oncol. Oct. 2000;79(1):50-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11006030].
Gregory H, Wordsworth S, Gibbons B, et al. Risk estimation for familial breast cancer: improving the system of counselling. Eur J Hum Genet. Nov. 2007;15(11):1139-44. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17637807].
Griffin SJ, Little PS, Hales CN, et al. Diabetes risk score: Towards earlier detection or type 2 diabetes in general practice. Diabetes Metab Res Rev. 2000;16(3):164-71. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10867715].
Grigoroiu-Serbanescu M, Nothen MM, Ohlraun S, et al. Family history influences age of onset in bipolar I disorder in females but not in males. Am J Med Genet B Neuropsychiatr Genet. 2005;133(1):6-11. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Grill V, Persson G, Carlsson S, et al. Family history of diabetes in middle-aged Swedish men is a gender unrelated factor which associates with insulinopenia in newly diagnosed diabetic subjects. Diabetologia. Jan. 1999;42(1):15-23. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Groop L, Forsblom C, Lehtovirta M, et al. Metabolic consequences of a family history of NIDDM (the Botnia study): evidence for sex-specific parental effects. Diabetes. Nov. 1996;45(11):1585-93. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8866565].
Grosz A, Toth E, Peter I. A 10-year follow-up of ischemic heart disease risk factors in military pilots. Mil Med. 2007;172(2):214-9. Excluded because no eligible outcomes presented. [pmid: 17357781].
Grotto I, Huerta M, Kark JD, et al. Relation of parental history of coronary heart disease to obesity in young adults. Int J Obes Relat Metab Disord. Mar. 2003;27(3):362-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12629564].
Grover S, Stoffel EM, Bussone L, et al. Physician assessment of family cancer history and referral for genetic evaluation in colorectal cancer patients. Clin Gastroenterol Hepatol. Sep. 2004;2(9):813-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15354282].
Grunberg H, Thetloff M. The cardiovascular risk factor profile of Estonian school children. Acta Paediatr. 1998;87(1):37-42. Excluded because no eligible outcomes presented. [pmid: 9510445].
Grunig E, Tasman JA, Kucherer H, et al. Frequency and phenotypes of familial dilated cardiomyopathy. J Am Coll Cardiol. Jan. 1998;31(1):186-94. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9426039].
Guerrer-Romer F, Rodriguez-Moran M, Gonzalez-Ortiz M, et al. Insulin action and secretion in healthy Hispanic-Mexican first-degree relatives of subjects with type 2 diabetes. J Endocrinol Invest. Sep. 2001;24(8):580-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11686540].
Guerrero-Romero F, Rodriguez-Moran M. Prevalence of dyslipidemia in non-obese prepubertal children and its association with family history of diabetes, high blood pressure, and obesity. Arch Med Res. Nov. 2006;37(8):1015-21. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17045120].
Guillem JG, Bastar AL, Ng J, et al. Clustering of colorectal cancer in families of probands under 40 years of age. Dis Colon Rectum. Sep. 1996;39(9):1004-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8797650].
Guirguis-Blake J. Cancer genetic risk assessment for individuals at risk of familial breast cancer. Am Fam Physician. 2008;77(4):450-2. Excluded because not an eligible study design.
Gunaid AA, El Khally FMY, Hassan NAGM, et al. Demographic and clinical features of diabetes mellitus in 1095 Yemeni patients. Ann Saudi Med. 1997;17(4):402-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17353590].
Hadaegh F, Bozorgmanesh MR, Ghasemi A, et al. High prevalence of undiagnosed diabetes and abnormal glucose tolerance in the Iranian urban population: Tehran Lipid and Glucose Study. BMC Public Health. 2008;8:176. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18501007].
Hadfield SG, Horara S, Starr BJ, et al. Are patients with familial hypercholesterolaemia well managed in lipid clinics? An audit of eleven clinics from the Department of Health Familial Hypercholesterolaemia Cascade Testing project. Ann Clin Biochem. 2008;45(2):199-205. Excluded because no eligible outcomes presented. [pmid: 18325186].
Haines L, Wan KC, Lynn R, et al. Rising incidence of type 2 diabetes in children in the U.K. Diabetes Care. 2007;30(5):1097-101. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17259470].
Halapy EE, Chiarelli AM, Klar N, et al. Breast screening outcomes in women with and without a family history of breast and/or ovarian cancer. J Med Screen. 2004;11(1):32-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15006112].
Hall IJ, Burke W, Coughlin S, et al. Population-based estimates of the prevalence of family history of cancer among women. Community Genet. 2001;4(3):134-42. Excluded because no eligible outcomes presented. [pmid: 14960905].
Hall NR, Bishop DT, Stephenson BM, et al. Hereditary susceptibility to colorectal cancer. Relatives of early onset cases are particularly at risk. Dis Colon Rectum. Jul. 1996;39(7):739-43. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8674364].
Hallowell N, Murton F, Statham H, et al. Women's need for information before attending genetic counselling for familial breast or ovarian cancer: a questionnaire, interview, and observational study. BMJ. Jan. 25. 1997;314(7076):281-3. Excluded because no eligible outcomes presented. [pmid: 9022494].
Halmerbauer G, Gartner C, Schierl M, et al. Study on the Prevention of Allergy in Children in Europe (SPACE): Allergic sensitization at 1 year of age in a controlled trial of allergen avoidance from birth. Pediatr Allergy Immunol. 2003;14(1):10-7. Excluded because no eligible outcomes presented. [pmid: 12603706].
Hamid ZA, Kariem KA, Rashid MS, et al. Prevalence of Type 2 diabetes mellitus and impaired glucose tolerance in the Kashmir Valley of the Indian subcontinent. Diabetes Res Clin Pract. 2000;47(2):135-46. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10670914].
Harada K, Karube Y, Saruhara H, et al. Workplace hypertension is associated with obesity and family history of hypertension. Hypertens Res. Dec. 2006;29(12):969-76. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17378369].
Haraguchi S, Koizumi K, Hioki M, et al. Hereditary factors in multiple primary malignancies associated with lung cancer. Surg Today. 2007;37(5):375-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17468817].
Harder T, Franke K, Kohlhoff R, et al. Maternal and paternal family history of diabetes in women with gestational diabetes or insulin-dependent diabetes mellitus type I. Gynecol Obstet Invest. 2001;51(3):160-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11306901].
Harpaz D, Behar S, Rozenman Y, et al. Family history of coronary artery disease and prognosis after first acute myocardial infarction in a national survey. Cardiology. 2004;102(3):140-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15334023].
Harrop J, Chinn S, Verlato G, et al. Eczema, atopy and allergen exposure in adults: A population-based study. Clin Exp Allergy. 2007;37(4):526-35. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17430349].
Hartmann LC, Sellers TA, Frost MH, et al. Benign breast disease and the risk of breast cancer. N Engl J Med. 2005;353(3):229-37. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16034008].
Harwood DG, Barker WW, Ownby RL, et al. Family history of dementia and current depression in nondemented community-dwelling older adults. J Geriatr Psychiatry Neurol. 2000;13(2):65-71. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10912727].
Hauner H, Hanisch J, Bramlage P, et al. Prevalence of undiagnosed type-2-diabetes mellitus and impaired fasting glucose in German primary care: Data from the German metabolic and cardiovascular risk project (GEMCAS). Exp Clin Endocrinol Diabetes. 2008;116(1):18-25. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17926235].
Hawe E, Talmud PJ, Miller GJ, et al. Family history is a coronary heart disease risk factor in the Second Northwick Park Heart Study. Ann Hum Genet. Mar. 2003;67(Pt:2):97-106. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12675686].
Hayes RB, Liff JM, Pottern LM, et al. Prostate cancer risk in U.S. blacks and whites with a family history of cancer. Int J Cancer. Jan. 27. 1995;60(3):361-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 7829245].
Hebert-Croteau N, Goggin P, Kishchuk N. Estimation of breast cancer risk by women aged 40 and over: A population-based study. Can J Public Health. 1997;88(6):392-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9458566].
Heidari Z, Mahmoudzadeh-Sagheb HR, Sakhavar N. Breast cancer screening knowledge and practice among women in southeast of Iran. Acta Med Iran. 2008;46(4):321-8. Excluded because no eligible outcomes presented.
Hemminki K, Vaittinen P. Effect of paternal and maternal cancer on cancer in the offspring: A population-based study. Cancer Epidemiol Biomarkers Prev. 1997;6(12):993-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9419393].
Hemminki K, Vaittinen P. Familial risks in in situ cancers from the Family-Cancer Database. Cancer Epidemiol Biomarkers Prev. Oct. 1998;7(10):865-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9796630].
Hemminki K, Granstrom C, Czene K. Attributable risks for familial breast cancer by proband status and morphology: a nationwide epidemiologic study from Sweden. Int J Cancer. Jul. 10. 2002;100(2):214-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12115572].
Hemminki K, Czene K. Age specific and attributable risks of familial prostate carcinoma from the family-cancer database. Cancer. Sep. 15. 2002;95(6):1346-53. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12216104].
Hemminki K, Chen B. Familial association of colorectal adenocarcinoma with cancers at other sites. Eur J Cancer. Nov. 2004;40(16):2480-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15519523].
Hemminki K, Granstrom C. Familial clustering of ovarian and endometrial cancers. Eur J Cancer. Jan. 2004;40(1):90-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14687794].
Hemminki K, Chen B. Familial association of prostate cancer with other cancers in the Swedish Family-Cancer Database. Prostate. Oct. 1. 2005;65(2):188-94. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15948149].
Hemminki K, Li X. Familial risk for lung cancer by histology and age of onset: evidence for recessive inheritance. Exp Lung Res. Mar. 2005;31(2):205-15. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15824021].
Hemminki K, Ji J, Forsti A. Risks for familial and contralateral breast cancer interact multiplicatively and cause a high risk. Cancer Res. Feb. 1. 2007;67(3):868-70. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17283115].
Hemminki K, Forsti A, Sundquist J, et al. Risk of familial breast cancer is not increased after pregnancy. Breast Cancer Res Treat. 2008;108(3):417-20. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17522974].
Hemminki K, Zhang H, Sundquist J, et al. Modification of risk for subsequent cancer after female breast cancer by a family history of breast cancer. Breast Cancer Res Treat. 2008;111(1):165-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17899363].
Henderson BJ, Tyndel S, Brain K, et al. Factors associated with breast cancer-specific distress in younger women participating in a family history mammography screening programme. Psychooncology. Jan. 2008;17(1):74-82. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17410528].
Hersberger KE, Botomino A, Mancini M, et al. Sequential screening for diabetes--evaluation of a campaign in Swiss community pharmacies. Pharm World Sci. Jun. 2006;28(3):171-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17004016].
Hershey CO, Grant BJ. Controlled trial of a patient-completed history questionnaire: effects on quality of documentation and patient and physician satisfaction. Am J Med Qual. Jul. 2002;17(4):126-35. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12153065].
Higgins PS, Wakefield D, Cloutier MM. Risk factors for asthma and asthma severity in nonurban children in Connecticut. Chest. 2005;128(6):3846-53. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16354853].
Hijazi N, Abalkhail B, Seaton A. Diet and childhood asthma in a society in transition: A study in urban and rural Saudi Arabia. Thorax. 2000;55(9):775-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10950897].
Hill DA, Preston-Martin S, Ross RK, et al. Medical radiation, family history of cancer, and benign breast disease in relation to breast cancer risk in young women, USA. Cancer Causes Control. Oct. 2002;13(8):711-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12420949].
Hines LM, Risendal B, Slattery ML, et al. Differences in estrogen receptor subtype according to family history of breast cancer among Hispanic, but not non-Hispanic White women. Cancer Epidemiol Biomarkers Prev. Oct. 2008;17(10):2700-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18843012].
Hippisley-Cox J, Coupland C, Vinogradova Y, et al. Derivation and validation of QRISK, a new cardiovascular disease risk score for the United Kingdom: prospective open cohort study. BMJ. Jul. 21. 2007;335(7611):136. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17615182].
Hippisley-Cox J, Coupland C, Vinogradova Y, et al. Predicting cardiovascular risk in England and Wales: prospective derivation and validation of QRISK2. BMJ. Jun. 28. 2008;336(7659):1475-82. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18573856].
Hiripi E, Bermejo JL, Sundquist J, et al. Association of colorectal adenoma with other malignancies in Swedish families. Br J Cancer. Mar. 11. 2008;98(5):997-1000. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18283306].
Hirose K, Tajima K, Hamajima N, et al. A large-scale, hospital-based case-control study of risk factors of breast cancer according to menopausal status. Jpn J Cancer Res. Feb. 1995;86(2):146-54. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 7730137].
Hirose K, Tajima K, Hamajima N, et al. Impact of family history on the risk of breast cancer among the Japanese. Jpn J Cancer Res. Dec. 1997;88(12):1130-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9473729].
Hirose K, Tajima K, Hamajima N, et al. Association of family history and other risk factors with breast cancer risk among Japanese premenopausal and postmenopausal women. Cancer Causes Control. May. 2001;12(4):349-58. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11456231].
Hlavaty T, Lukac L, Huorka M, et al. Positive family history promotes participation in colorectal cancer screening. Bratisl Lek Listy. 2005;106(10):318-23. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16541612].
Hollman G, Olsson AG, Ek AC. Familial hypercholesterolaemia and quality of life in family members. Prev Med. May. 2003;36(5):569-74. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12689802].
Hopkins PN, Ellison RC, Province MA, et al. Association of Coronary Artery Calcified Plaque With Clinical Coronary Heart Disease in the National Heart, Lung, and Blood Institute's Family Heart Study. Am J Cardiol. 2006;97(11):1564-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16728214].
Hornsby-Lewis L. Family history increases the risk of colorectal cancer. Gastroenterology. Sep. 1995;109(3):1015-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 7657089].
House W, Sharp D, Sheridan E. Identifying and screening patients at high risk of colorectal cancer in general practice. J Med Screen. 1999;6(4):205-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10693067].
Hu G, Tian H. A comparison of dietary and non-dietary factors of hypertension and normal blood pressure in a Chinese population. J Hum Hypertens. 2001;15(7):487-93. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11464259].
Huang D, Guan P, Shi H, et al. Reliability and accuracy of interview data in non-smoking female lung cancer case-control study. J Exp Clin Cancer Res. 2008;27(1). Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Huang JL, Chen CC, Kuo ML, et al. Exposure to a high concentration of mite allergen in early infancy is a risk factor for developing atopic dermatitis: a 3-year follow-up study. Pediatr Allergy Immunol. Feb. 2001;12(1):11-6. Excluded because no eligible outcomes presented. [pmid: 11251859].
Hughes KS, Roche C, Campbell CT, et al. Prevalence of family history of breast and ovarian cancer in a single primary care practice using a self-administered questionnaire. Breast J. Jan. 2003;9(1):19-25. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12558666].
Hunt KJ, Heiss G, Sholinsky PD, et al. Familial history of metabolic disorders and the multiple metabolic syndrome: the NHLBI family heart study. Genet Epidemiol. Dec. 2000;19(4):395-409. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11108648].
Hunter A, Vimplis S, Sharma A, et al. To determine whether first-degree male relatives of women with polycystic ovary syndrome are at higher risk of developing cardiovascular disease and type II diabetes mellitus. J Obstet Gynaecol. Aug. 2007;27(6):591-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17896258].
Hurrell C, Wietlisbach V, Jotterand V, et al. High prevalence of major cardiovascular risk factors in first-degree relatives of individuals with familial premature coronary artery disease--the GENECARD project. Atherosclerosis. Sep. 2007;194(1):253-64. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16965774].
Husseini A, Abdul-Rahim H, Awartani F, et al. Type 2 diabetes mellitus, impaired glucose tolerance and associated factors in a rural palestinian village. Diabet Med. 2000;17(10):746-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11110509].
Husseini A, Abdul-Rahim H, Giacaman R, et al. Selected factors associated with diabetes mellitus in a rural Palestinian community. Med Sci Monit. 2003;9(5):CR181-CR185. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12761454].
Hyland F, Kinmonth AL, Marteau TM, et al. Raising concerns about family history of breast cancer in primary care consultations: prospective, population based study. Women's Concerns Study Group. BMJ. Jan. 6. 2001;322(7277):27-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11141150].
Imperiale TF, Kahi CJ, Stuart JS, et al. Risk factors for advanced sporadic colorectal neoplasia in persons younger than age 50. Cancer Detect Prev. 2008;32(1):33-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18400417].
Iqbal Hydrie MZ, Basit A, Ahmedani MY, et al. Comparison of risk factors for diabetes in children of different socioeconomic status. J Coll Physicians Surg Pak. 2005;15(2):74-7. Excluded because no eligible outcomes presented. [pmid: 15730829].
Iqbal SP, Dodani S, Qureshi R. Risk factors and behaviours for coronary artery disease (CAD) among ambulatory Pakistanis. J Pak Med Assoc. 2004;54(5):261-6. Excluded because no eligible outcomes presented. [pmid: 15270186].
Irving RR, Mills JL, Choo-Kang EG, et al. The burden of gestational diabetes mellitus in Jamaican women with a family history of autosomal dominant type 2 diabetes. Rev Panam Salud Publica. Feb. 2008;23(2):85-91. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18371278].
Irving RR, Mills JL, Choo-Kang EG, et al. Diabetes and psychological comorbidity in children with a family history of early-onset type 2 diabetes. Int J Psychol. Dec. 2008;43(6):937-42. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Ishikawa M, Pruneda ML, Adams-Huet B, et al. Obesity-independent hyperinsulinemia in nondiabetic first-degree relatives of individuals with type 2 diabetes. Diabetes. May. 1998;47(5):788-92. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9588451].
Islam-Zwart K, Cawston A. Investigation of factors contributing to diabetes risk in american indian/alaska native youth. Am Indian Alsk Native Ment Health Res. 2008;14(3):49-58. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18286446].
Ivanovich J, Babb S, Goodfellow P, et al. Evaluation of the family history collection process and the accuracy of cancer reporting among a series of women with endometrial cancer. Clin Cancer Res. Jun. 2002;8(6):1849-56. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12060627].
Iwata F, Okada T, Harada K, et al. Coronary risk factors in school children in relation to their family history of coronary heart disease and hyperlipidemia. Acta Paediatr Jpn. Feb. 1998;40(1):30-4. Excluded because no eligible outcomes presented. [pmid: 9583197].
Jacobs LA. Health beliefs of first-degree relatives of individuals with colorectal cancer and participation in health maintenance visits: a population-based survey. Cancer Nurs. Aug. 2002;25(4):251-65. Excluded because no eligible outcomes presented. [pmid: 12181494].
Jacobsen PB, Lamonde LA, Honour M, et al. Relation of family history of prostate cancer to perceived vulnerability and screening behavior. Psychooncology. Feb. 2004;13(2):80-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14872526].
Jaddou HY, Batiehah AM, Ajlouni KM. Prevalence and associated factors of hypertension: Results from a three community-based survey, Jordan. J Hum Hypertens. 1996;10(12):815-21. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9140788].
Jakubowska A, Cybulski C, Szymanska A, et al. BARD1 and breast cancer in Poland. Breast Cancer Res Treat. Jan. 2008;107(1):119-22. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17333333].
Janda M, Obermair A, Haidinger G, et al. Austrian women's attitudes toward and knowledge of breast self-examination. J Cancer Educ. 2000;15(2):91-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10879898].
Jansson PA, Eliasson B, Lindmark S, et al. Endocrine abnormalities in healthy first-degree relatives of type 2 diabetes patients--potential role of steroid hormones and leptin in the development of insulin resistance. Eur J Clin Invest. Mar. 2002;32(3):172-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11895468].
Jarvinen HJ, Mecklin JP, Sistonen P. Screening reduces colorectal cancer rate in families with hereditary nonpolyposis colorectal cancer. Gastroenterology. May. 1995;108(5):1405-11. Excluded because no eligible outcomes presented. [pmid: 7729632].
Jaworowska E, Serrano-Fernandez P, Tarnowska C, et al. Familial association of laryngeal, lung, stomach and early-onset breast cancer. Breast Cancer Res Treat. Nov. 2008;112(2):359-61. Excluded because no eligible outcomes presented. [pmid: 18097745].
Jenei Z, Pall D, Katona E, et al. The epidemiology of hypertension and its associated risk factors in the city of Debrecen, Hungary. Public Health. 2002;116(3):138-44. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12082595].
Jerrard-Dunne P, Markus HS, Steckel DA, et al. Early carotid atherosclerosis and family history of vascular disease: specific effects on arterial sites have implications for genetic studies. Arterioscler Thromb Vasc Biol. Feb. 1. 2003;23(2):302-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12588775].
Jerrard-Dunne P, Cloud G, Hassan A, et al. Evaluating the genetic component of ischemic stroke subtypes: a family history study. Stroke. Jun. 2003;34(6):1364-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12714707].
Ji J, Hemminki K. Risk for contralateral breast cancers in a population covered by mammography: effects of family history, age at diagnosis and histology. Breast Cancer Res Treat. Oct. 2007;105(2):229-36. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17115107].
Ji J, Forsti A, Sundquist J, et al. Survival in ovarian cancer patients by histology and family history. Acta Oncol. 2008;47(6):1133-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18607880].
Jimenez-Moleon JJ, Bueno-Cavanillas A, Luna-del-Castillo JD, et al. Predictive value of a screen for gestational diabetes mellitus: Influence of associated risk factors. Acta Obstet Gynecol Scand. 2000;79(11):991-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11081686].
Jimenez-Moleon JJ, Bueno-Cavanillas A, Luna-del-Castillo JD, et al. Prevalence of gestational diabetes mellitus: Variations related to screening strategy used. EUR. 2002;146(6):831-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Jin Y, Xu Y, Xu M, et al. Increased risk of cancer among relatives of patients with lung cancer in China. BMC Cancer. 2005;5:146. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16281985].
Jin YT, Xu YC, Yang RD, et al. Familial aggregation of lung cancer in a high incidence area in China. Br J Cancer. Apr. 11. 2005;92(7):1321-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15756270].
Johns LE, Kee F, Collins BJ, et al. Colorectal cancer mortality in first-degree relatives of early-onset colorectal cancer cases. Dis Colon Rectum. May. 2002;45(5):681-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12004220].
Johnson CC, Ownby DR, Peterson EL. Parental history of atopic disease and concentration of cord blood IgE. Clin Exp Allergy. Jun. 1996;26(6):624-9. Excluded because no eligible outcomes presented. [pmid: 8809419].
Johnson J, Giles RT, Larsen L, et al. Utah's Family High Risk Program: bridging the gap between genomics and public health. Prev Chronic Dis. Apr. 2005;2(2):A24. Excluded because not an eligible study design. [pmid: 15888235].
Johnson KC, Pan S, Mao Y. Risk factors for male breast cancer in Canada, 1994–1998. Eur J Cancer Prev. 2002;11(3):253-63. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12131659].
Jones AP, Eyles E. Early life exposures and the prevalence of atopic disoders in a sample of school-age infants. Monaldi Arch Chest Dis. 2003;59(1):38-43. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14533281].
Jones JL, Hughes KS, Kopans DB, et al. Evaluation of hereditary risk in a mammography population. Clin Breast Cancer. Apr. 2005;6(1):38-44. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15899071].
Jonsson S, Thorsteinsdottir U, Gudbjartsson DF, et al. Familial risk of lung carcinoma in the Icelandic population. [erratum appears in JAMA. 2005 Jan 12;293(2):163]. JAMA. Dec. 22. 2004;292(24):2977-83. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15613665].
Jood K, Ladenvall C, Rosengren A, et al. Family history in ischemic stroke before 70 years of age: the Sahlgrenska Academy Study on Ischemic Stroke. Stroke. Jul. 2005;36(7):1383-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15933254].
Jousilahti P, Rastenyte D, Tuomilehto J, et al. Parental history of cardiovascular disease and risk of stroke. A prospective follow-up of 14371 middle-aged men and women in Finland. Stroke. Jul. 1997;28(7):1361-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9227684].
Joyce DP, Chapman KR, Balter M, et al. Asthma and allergy avoidance knowledge and behavior in postpartum women. Ann Allergy Asthma Immunol. Jul. 1997;79(1):35-42. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9236497].
Juonala M, Viikari JS, Rasanen L, et al. Young adults with family history of coronary heart disease have increased arterial vulnerability to metabolic risk factors: the Cardiovascular Risk in Young Finns Study. Arterioscler Thromb Vasc Biol. Jun. 2006;26(6):1376-82. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16614318].
Kadiki OA, Roaeid RB. Prevalence of diabetes mellitus and impaired glucose tolerance in Benghazi Libya. Diabetes Metab. 2001;27(6):647-54. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11852372].
Kaerlev L, Lynge E, Sabroe S, et al. Reliability of data from next-of-kin: results from a case-control study of occupational and lifestyle risk factors for cancer. Am J Ind Med. Sep. 2003;44(3):298-303. Excluded because family history not collected. [pmid: 12929150].
Kahn JS, Weseley AJ. When the third degree is necessary: Do pediatricians obtain enough information to detect patients at risk for HCM?. Pediatr Cardiol. 2008;29(3):589-96. Excluded because family history not collected. [pmid: 18049788].
Kaikkonen KS, Kortelainen ML, Linna E, et al. Family history and the risk of sudden cardiac death as a manifestation of an acute coronary event. Circulation. Oct. 3. 2006;114(14):1462-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17000909].
Kalyoncu AF, Selcuk ZT, Enunlu T, et al. Prevalence of asthma and allergic diseases in primary school children in Ankara, Turkey: Two cross-sectional studies, five years apart. Pediatr Allergy Immunol. 1999;10(4):261-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10678723].
Kanitz MG, Giovannucci SJ, Jones JS, et al. Myocardial infarction in young adults: Risk factors and clinical features. J Emerg Med. 1996;14(2):139-45. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8740743].
Karadzinska-Bislimovska J, Minov J, Risteska-Kuc S, et al. Bronchial hyperresponsiveness in women cooks and cleaners. Arh Hig Rada Toksikol. 2007;58(2):223-31. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17562606].
Kardia SL, Haviland MB, Sing CF. Correlates of family history of coronary artery disease in children. J Clin Epidemiol. Jun. 1998;51(6):473-86. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9635996].
Karlsson CT, Malmer B, Wiklund F, et al. Breast cancer as a second primary in patients with prostate cancer--estrogen treatment or association with family history of cancer?. J Urol. Aug. 2006;176(2):538-43. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16813884].
Karner-Hanusch J, Mittlbock M, Fillipitsch T, et al. Family history as a marker of risk for colorectal cancer: Austrian experience. World J Surg. Feb. 1997;21(2):205-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8995080].
Karunasekera KAW, Jayasinghe JACT, Alwis LWGR. Risk factors of childhood asthma: A Sri Lankan study. J Trop Pediatr. 2001;47(3):142-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11419676].
Katballe N, Juul S, Christensen M, et al. Patient accuracy of reporting on hereditary non-polyposis colorectal cancer-related malignancy in family members. Br J Surg. Sep. 2001;88(9):1228-33. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11531872].
Katelaris CH, Carrozzi FM, Burke TV, et al. Patterns of allergic reactivity and disease in Olympic athletes. Clin J Sport Med. 2006;16(5):401-5. Excluded because no eligible outcomes presented. [pmid: 17016116].
Katsouyanni K, Signorello LB, Lagiou P, et al. Evidence that adult life risk factors influence the expression of familial propensity to breast cancer. Epidemiology. Sep. 1997;8(5):592-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9270964].
Kavanagh T, Shephard RJ, Hamm LF, et al. Risk profile and health awareness in male offspring of parents with premature coronary heart disease. J Cardpulm Rehabil. May. 2000;20(3):172-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Kawano H, Soejima H, Kojima S, et al. Sex differences of risk factors for acute myocardial infarction in Japanese patients. Circ J. May. 2006;70(5):513-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16636482].
Kawasaki K, Kanemitsu K, Yasuda T, et al. Family history of cancer in Japanese gastric cancer patients. Gastric Cancer. 2007;10(3):173-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17922095].
Kazerouni N, Greene MH, Lacey JV Jr, et al. Family history of breast cancer as a risk factor for ovarian cancer in a prospective study. Cancer. Sep. 1. 2006;107(5):1075-83. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16881078].
Keetch DW, Rice JP, Suarez BK, et al. Familial aspects of prostate cancer: A case control study. J Urol. 1995;154(6):2100-2. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 7500468].
Kekalainen P, Sarlund H, Pyorala K, et al. Family history of coronary heart disease is a stronger predictor of coronary heart disease morbidity and mortality than family history of non-insulin dependent diabetes mellitus. Atherosclerosis. Jun. 1996;123(1–2):203-13. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8782851].
Kelishadi R, Ardalan G, Gheiratmand R, et al. Is family history of premature cardiovascular diseases appropriate for detection of dyslipidemic children in population-based preventive medicine programs? CASPIAN study. Pediatr Cardiol. Nov. 2006;27(6):729-36. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17111289].
Kelleher CC, Fallon UB, Fitzsimon N, et al. The risk factor profile of grandparents. Ir Med J. Sep. 2007;100(8):15-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17955695].
Keller M, Jost R, Haunstetter CM, et al. Psychosocial outcome following genetic risk counselling for familial colorectal cancer. A comparison of affected patients and family members. Clin Genet. Nov. 2008;74(5):414-24. Excluded because no eligible outcomes presented. [pmid: 18954412].
Kelly LA, Lane CJ, Weigensberg MJ, et al. Parental history and risk of type 2 diabetes in overweight Latino adolescents: a longitudinal analysis. Diabetes Care. Oct. 2007;30(10):2700-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17626894].
Kendler KS, Roy MA. Validity of a diagnosis of lifetime major depression obtained by personal interview versus family history. Am J Psychiatry. Nov. 1995;152(11):1608-14. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 7485623].
Kerber RA, Slattery ML. The impact of family history on ovarian cancer risk. The Utah Population Database. Arch Intern Med. May. 8. 1995;155(9):905-12. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 7726698].
Kerber RA, Slattery ML, Potter JD, et al. Risk of colon cancer associated with a family history of cancer or colorectal polyps: the diet, activity, and reproduction in colon cancer study. Int J Cancer. Oct. 5. 1998;78(2):157-60. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9754645].
Kerber RA, O'Brien E. A cohort study of cancer risk in relation to family histories of cancer in the Utah population database. Cancer. 2005;103(9):1906-15. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15779016].
Kerr B, Foulkes WD, Cade D, et al. False family history of breast cancer in the family cancer clinic. Eur J Surg Oncol. Aug. 1998;24(4):275-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9724992].
Khuwaja AK, Fatmi Z, Soomro WB, et al. Risk Factors for Cardiovascular Disease in School Children - A Pilot Study. J Pak Med Assoc. 2003;53(9):396-400. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14620313].
Kilfoy BA, Zhang Y, Shu XO, et al. Family history of malignancies and risk of breast cancer: prospective data from the Shanghai women's health study. Cancer Causes Control. Dec. 2008;19(10):1139-45. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18575953].
Kim CW, Park CJ, Kim JW, et al. Prevalence of atopic dermatitis in Korea. Acta Derm Venereol. 2000;80(5):353-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11200833].
Kim H, Friedlander Y, Longstreth WT Jr, et al. Family history as a risk factor for stroke in young women. Am J Prev Med. Dec. 2004;27(5):391-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15556739].
Kim SM, Lee JS, Lee J, et al. Prevalence of diabetes and impaired fasting glucose in Korea: Korean National Health and Nutrition Survey 2001. Diabetes Care. 2006;29(2):226-31. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16443864].
King CA, Knox MS, Henninger N, et al. Major depressive disorder in adolescents: family psychiatric history predicts severe behavioral disinhibition. J Affect Disord. Feb. 2006;90(2–3):111-21. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16352346].
King M, Walker C, Levy G, et al. Development and validation of an international risk prediction algorithm for episodes of major depression in general practice attendees: The predictD study. Arch Gen Psychiatry. 2008;65(12):1368-76. Excluded because no eligible outcomes presented. [pmid: 19047523].
Kinmonth AL, Wareham NJ, Hardeman W, et al. Efficacy of a theory-based behavioural intervention to increase physical activity in an at-risk group in primary care (ProActive UK): A randomised trial. Lancet. Jan. 2008;371(9606):41-8. Excluded because no eligible outcomes presented. [pmid: 18177774].
Kinney AY, Hicken B, Simonsen SE, et al. Colorectal cancer surveillance behaviors among members of typical and attenuated FAP families. Am J Gastroenterol. Jan. 2007;102(1):153-62. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17266693].
Klein Woolthuis EP, de Grauw WJC, van Gerwen WHEM, et al. Identifying people at risk for undiagnosed type 2 diabetes using the GP's electronic medical record. Fam Pract. 2007;24(3):230-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17510087].
Klein BE, Klein R, Moss SE, et al. Parental history of diabetes in a population-based study. Diabetes Care. Aug. 1996;19(8):827-30. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8842599].
Klein DN, Lewinsohn PM, Seeley JR, et al. A family study of major depressive disorder in a community sample of adolescents. Arch Gen Psychiatry. Jan. 2001;58(1):13-20. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11146753].
Klein DN, Shankman SA, Lewinsohn PM, et al. Family study of chronic depression in a community sample of young adults. Am J Psychiatry. Apr. 2004;161(4):646-53. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15056510].
Knuiman MW, Divitini ML, Welborn TA, et al. Familial correlations, cohabitation effects, and heritability for cardiovascular risk factors. Ann Epidemiol. May. 1996;6(3):188-94. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8827153].
Ko GTC, Chan JCN, Tsang LWW, et al. Outcomes of screening for diabetes in high-risk Hong Kong Chinese subjects. Diabetes Care. 2000;23(9):1290-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10977020].
Ko GTC, Chan JCN, Tsang LWW, et al. Smoking and diabetes in Chinese men. Postgrad Med J. 2001;77(906):240-3. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11264486].
Kocic B, Petrovic B, Filipovic S. Risk factors for breast cancer: A hospital-based case-control study. J BUON. 2008;13(2):231-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18555470].
Kodali VR, Seshaiah V, Moses SG. Body mass index and family histories in type II diabetic propositi and preliminary observations on the transmission of diabetes in polygamous families. Hum Biol. Jun. 1997;69(3):393-402. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9164049].
Koehly LM, Peters JA, Kuhn N, et al. Sisters in hereditary breast and ovarian cancer families: Communal coping, social integration, and psychological well-being. Psychooncology. 2008;17(8):812-21. Excluded because not an eligible population. [pmid: 18688790].
Koh YY, Lee MH, Sun YH, et al. Improvement in bronchial hyperresponsiveness with inhaled corticosteroids in children with asthma: importance of family history of bronchial hyperresponsiveness. Am J Respir Crit Care Med. Aug. 1. 2002;166(3):340-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12153967].
Kojo K, Pukkala E, Auvinen A. Breast cancer risk among Finnish cabin attendants: A nested case-control study. Occup Environ Med. 2005;62(7):488-93. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15961626].
Kok ET, Schouten BW, Bohnen AM, et al. Risk factors for lower urinary tract symptoms suggestive of benign prostatic hyperplasia in a community based population of healthy aging men: the Krimpen Study. J Urol. Feb. 2009;181(2):710-6. Excluded because no eligible outcomes presented. [pmid: 19091352].
Koopman RJ, Mainous AG III, Everett CJ, et al. Tool to assess likelihood of fasting glucose impairment (TAG-IT). Ann Fam Med. 2008;6(6):555-61. Excluded because no eligible outcomes presented. [pmid: 19001309].
Kotake K, Koyama Y, Nasu J, et al. Relation of family history of cancer and environmental factors to the risk of colorectal cancer: a case-control study. Jpn J Clin Oncol. Oct. 1995;25(5):195-202. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 7474407].
Kovacs M, Devlin B, Pollock M, et al. A controlled family history study of childhood-onset depressive disorder. Arch Gen Psychiatry. Jul. 1997;54(7):613-23. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9236545].
Kreuzer M, Kreienbrock L, Gerken M, et al. Risk factors for lung cancer in young adults. Am J Epidemiol. Jun. 1. 1998;147(11):1028-37. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9620046].
Kronmal RA, McClelland RL, Detrano R, et al. Risk factors for the progression of coronary artery calcification in asymptomatic subjects: Results from the Multi-Ethnic Study of Atherosclerosis (MESA). Circulation. 2007;115(21):2722-30. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17502571].
Kubota M, Yamaura A, Ono J, et al. Is family history an independent risk factor for stroke?. J Neurol Neurosurg Psychiatry. Jan. 1997;62(1):66-70. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9010402].
Kumar R, Wang B, Wang X, et al. Bronchodilator responses in Chinese children from asthma index families and the general population. J Allergy Clin Immunol. 2006;117(6):1257-63. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16750984].
Kummeling I, Thijs C, Penders J, et al. Etiology of atopy in infancy: the KOALA Birth Cohort Study. Pediatr Allergy Immunol. Dec. 2005;16(8):679-84. Excluded because no eligible outcomes presented. [pmid: 16343090].
Kupfer SS, McCaffrey S, Kim KE. Racial and gender disparities in hereditary colorectal cancer risk assessment: the role of family history. J Cancer Educ. 2006;21(Suppl 1):S31-S36. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Kuriki K, Hirose K, Tajima K. Diabetes and cancer risk for all and specific sites among Japanese men and women. Eur J Cancer Prev. Feb. 2007;16(1):83-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17220709].
Kuru B, Ozaslan C, Ozdemir P, et al. Risk factors for breast cancer in Turkish women with early pregnancies and long-lasting lactation - A case-control study. Acta Oncol. 2002;41(6):556-61. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12546529].
Kurukulaaratchy RJ, Matthews S, Arshad SH. Relationship between childhood atopy and wheeze: what mediates wheezing in atopic phenotypes?. Ann Allergy Asthma Innunol. Jul. 2006;97(1):84-91. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Kushner JD, Nauman D, Burgess D, et al. Clinical characteristics of 304 kindreds evaluated for familial dilated cardiomyopathy. J Card Fail. Aug. 2006;12(6):422-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16911908].
Lagos VI, Perez MA, Ricker CN, et al. Social-cognitive aspects of underserved Latinas preparing to undergo genetic cancer risk assessment for hereditary breast and ovarian cancer. Psychooncology. 2008;17(8):774-82. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18646245].
Laing SS, Makambi K. Predicting regular breast cancer screening in African-American women with a family history of breast cancer. J Natl Med Assoc. Nov. 2008;100(11):1309-17. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 19024228].
Lam DSY, Leung SP, So KT. Age of onset of asthma symptoms. HK J Paediatr. 2007;12(1):11-4+61. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Lancaster DR. Coping with appraised breast cancer risk among women with family histories of breast cancer. Res Nurs Health. Apr. 2005;28(2):144-58. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15779052].
Langdeau J-B, Turcotte H, Thibault G, et al. Comparative prevalence of asthma in different groups of athletes: A survey. Can Respir J. 2004;11(6):402-6. Excluded because no eligible outcomes presented. [pmid: 15510247].
Larsen FS, Diepgen T, Svensson A. The occurrence of atopic dermatitis in North Europe: An international questionnaire study. J Am Acad Dermatol. 1996;34(5 I):760-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8632070].
Lascaux-Lefebvre V, Ruidavets JB, Arveiler D, et al. Influence of parental histories of cardiovascular risk factors on risk factor clusters in the offspring. Diabetes Metab. 2001;27(4 I):503-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11547225].
Latzin P, Beck J, Griese M. Exhaled nitric oxide in healthy children: variability and a lack of correlation with atopy. Pediatr Allergy Immunol. Feb. 2002;13(1):37-46. Excluded because no eligible outcomes presented. [pmid: 12000497].
Laubereau B, Brockow I, Zirngibl A, et al. Effect of breast-feeding on the development of atopic dermatitis during the first 3 years of life - Results from the gini-birth cohort study. J Pediatr. 2004;144(5):602-7. Excluded because no eligible outcomes presented. [pmid: 15126993].
Laukkanen JA, Rauramaa R, Salonen JT, et al. The predictive value of cardiorespiratory fitness combined with coronary risk evaluation and the risk of cardiovascular and all-cause death. J Intern Med. 2007;262(2):263-72. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17645594].
Lawrence JM, Bennett P, Young A, et al. Screening for diabetes in general practice: Cross sectional population study. Br Med J. 2001;323(7312):548-51. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11546702].
Le Marchand L, Zhao LP, Quiaoit F, et al. Family history and risk of colorectal cancer in the multiethnic population of Hawaii. Am J Epidemiol. Dec. 15. 1996;144(12):1122-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8956624].
Le Marchand L, Wilkens LR, Hankin JH, et al. Independent and joint effects of family history and lifestyle on colorectal cancer risk: Implications for prevention. Cancer Epidemiol Biomarkers Prev. 1999;8(1):45-51. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9950239].
Leander K, Hallqvist J, Reuterwall C, et al. Family history of coronary heart disease, a strong risk factor for myocardial infarction interacting with other cardiovascular risk factors: results from the Stockholm Heart Epidemiology Program (SHEEP). Epidemiology. Mar. 2001;12(2):215-21. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11246583].
Lecomte P, Vol S, Caces E, et al. Five-year predictive factors of type 2 diabetes in men with impaired fasting glucose. Diabetes Metab. 2007;33(2):140-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17320447].
Lee EO, Ahn SH, You C, et al. Determining the main risk factors and high-risk groups of breast cancer using a predictive model for breast cancer risk assessment in South Korea. Cancer Nurs. Sep. 2004;27(5):400-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15525868].
Lee ET, Howard BV, Savage PJ, et al. Diabetes and impaired glucose tolerance in three American Indian populations aged 45–74 years: The strong heart study. Diabetes Care. 1995;18(5):599-610. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8585996].
Lee JT, Lam ZC, Lee WT, et al. Familial risk of allergic rhinitis and atopic dermatitis among Chinese families in Singapore. Ann Acad Med Singapore. Jan. 2004;33(1):71-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15008567].
Lee W-Y, Jung C-H, Park J-S, et al. Effects of smoking, alcohol, exercise, education, and family history on the metabolic syndrome as defined by the ATP III. Diabetes Res Clin Pract. 2005;67(1):70-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15620436].
Leggatt V, Mackay J, Yates JR. Evaluation of questionnaire on cancer family history in identifying patients at increased genetic risk in general practice. BMJ. Sep. 18. 1999;319(7212):757-8. Excluded because no eligible outcomes presented. [pmid: 10488003].
Lehmann I, Thoelke A, Weiss M, et al. T cell reactivity in neonates from an East and a West German city - Results of the LISA study. Allergy. 2002;57(2):129-36. Excluded because no eligible outcomes presented. [pmid: 11929415].
Lerbaek A, Kyvik KO, Mortensen J, et al. Heritability of hand eczema is not explained by comorbidity with atopic dermatitis. J Invest Dermatol. Jul. 2007;127(7):1632-40. Excluded because family history not collected. [pmid: 17301829].
Lesko SM, Rosenberg L, Shapiro S. Family history and prostate cancer risk. Am J Epidemiol. Dec. 1. 1996;144(11):1041-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8942435].
Leu M, Reilly M, Czene K. Evaluation of bias in familial risk estimates: A study of common cancers using Swedish population-based registers. J Natl Cancer Inst. 2008;100(18):1318-25. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18780865].
Leung R, Ho P, Lam CW, et al. Sensitization to inhaled allergens as a risk factor for asthma and allergic diseases in Chinese population. J Allergy Clin Immunol. May. 1997;99(5):594-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9155823].
Leung TF, Tam WH, Hung ECW, et al. Sociodemographic and atopic factors affecting breastfeeding intention in Chinese mothers. J Paediatr Child Health. 2003;39(6):460-4. Excluded because no eligible outcomes presented. [pmid: 12919502].
Levesque B, Rhainds M, Ernst P, et al. Asthma and allergic rhinitis in Quebec children. Can Respir J. 2004;11(5):343-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15332136].
Levesque B, Duchesne J-F, Gingras S, et al. Total and specific immunoglobulin E and their relationship to respiratory symptoms in Quebec children and adolescents. Can Respir J. 2005;12(8):426-32. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16331314].
Levy AG, Shea J, Williams SV, et al. Measuring perceptions of breast cancer risk. Cancer Epidemiol Biomarkers Prev. 2006;15(10):1893-8. Excluded because no eligible outcomes presented. [pmid: 17035396].
Lewinsohn PM, Rohde P, Seeley JR, et al. Natural course of adolescent major depressive disorder in a community sample: predictors of recurrence in young adults. Am J Psychiatry. Oct. 2000;157(10):1584-91. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11007711].
Li G, Aryan M, Silverman JM, et al. The validity of the family history method for identifying Alzheimer disease. Arch Neurol. May. 1997;54(5):634-40. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9152121].
Li H, Xu T, Tong W, et al. Comparison of cardiovascular risk factors between prehypertension and hypertension in a Mongolian population, Inner Mongolia, China. Circ J. Oct. 2008;72(10):1666-73. Excluded because no eligible outcomes presented. [pmid: 18753701].
Li R, Bensen JT, Hutchinson RG, et al. Family risk score of coronary heart disease (CHD) as a predictor of CHD: the Atherosclerosis Risk in Communities (ARIC) study and the NHLBI family heart study. Genet Epidemiol. Mar. 2000;18(3):236-50. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10723108].
Li R, Gilliland FD, Baumgartner KB, et al. Family history and risk of breast cancer in hispanic and non-hispanic women: the New Mexico Women's Health Study. Cancer Causes Control. Oct. 2001;12(8):747-53. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11562115].
Li X, Hemminki K. Inherited predisposition to early onset lung cancer according to histological type. Int J Cancer. Nov. 10. 2004;112(3):451-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15382071].
Li X, Hemminki K. Familial multiple primary lung cancers: a population-based analysis from Sweden. Lung Cancer. Mar. 2005;47(3):301-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15713513].
Li X, Sundquist J, Sundquist K. Age-specific familial risks of depression: A nation-wide epidemiological study from Sweden. J Psychiatr Res. Aug. 2008;42(10):808-14. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17983628].
Liang PH, Shyur SD, Huang LH, et al. Risk factors and characteristics of early-onset asthma in Taiwanese children. J Microbiol Immunol Infect. Oct. 2006;39(5):414-21. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17066205].
Liao D, Myers R, Hunt S, et al. Familial history of stroke and stroke risk. The Family Heart Study. Stroke. Oct. 1997;28(10):1908-12. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9341694].
Lidfeldt J, Nyberg P, Nerbrand C, et al. Biological factors are more important than socio-demographic and psychosocial conditions in relation to hypertension in middle-aged women. The Women's Health in the Lund Area (WHILA) Study. Blood Press. 2002;11(5):270-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12458649].
Lieb R, Isensee B, Hofler M, et al. Parental major depression and the risk of depression and other mental disorders in offspring: a prospective-longitudinal community study. Arch Gen Psychiatry. Apr. 2002;59(4):365-74. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11926937].
Lieberman DA, Prindiville S, Weiss DG, et al. Risk factors for advanced colonic neoplasia and hyperplastic polyps in asymptomatic individuals. JAMA. Dec. 10. 2003;290(22):2959-67. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14665657].
Lightfoot N, Conlon M, Kreiger N, et al. Medical history, sexual, and maturational factors and prostate cancer risk. Ann Epidemiol. Oct. 2004;14(9):655-62. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15380796].
Lindahl MG, Barrett R, Peterson D, et al. Development of an integrative patient history intake tool: a Delphi study. Altern Ther Health Med. Jan. 2005;11(1):52-6. Excluded because family history not collected. [pmid: 15712766].
Lindgren A, Lovkvist H, Hallstrom B, et al. Prevalence of stroke and vascular risk factors among first-degree relatives of stroke patients and control subjects. A prospective consecutive study. Cerebrovasc Dis. 2005;20(5):381-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16205056].
Lindstrom M, Kotaniemi J, Jonsson E, et al. Smoking, respiratory symptoms, and diseases: A comparative study between northern Sweden and northern Finland: Report from the FinEsS study. Chest. 2001;119(3):852-61. Excluded because no eligible outcomes presented. [pmid: 11243968].
Lippert MT, Eaker ED, Vierkant RA, et al. Breast cancer screening and family history among rural women in Wisconsin. Cancer Detect Prev. 1999;23(3):265-72. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10337006].
Lisabeth LD, Kardia SL, Smith MA, et al. Family history of stroke among Mexican-American and non-Hispanic white patients with stroke and TIA: implications for the feasibility and design of stroke genetics research. Neuroepidemiology. 2005;24(1–2):96-102. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15459516].
Lisabeth LD, Smith MA, Brown DL, et al. Family history and stroke outcome in a bi-ethnic, population-based stroke surveillance study. BMC Neurol. 2005;5:20. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16262890].
Liu X, Sennett C, Legorreta AP. Mammography utilization among California women age 40–49 in a managed care environment. Breast Cancer Res Treat. May. 2001;67(2):181-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11519867].
Lizardi H, Klein DN. Parental psychopathology and reports of the childhood home environment in adults with early-onset dysthymic disorder. J Nerv Ment Dis. Feb. 2000;188(2):63-70. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10695833].
Loader S, Shields C, Levenkron JC, et al. Patient vs. physician as the target of educational outreach about screening for an inherited susceptibility to colorectal cancer. Genet Test. 2002;6(4):281-90. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12537652].
Lodrup Carlsen KC, Pettersen M, Carlsen K-H. Is bronchodilator response in 2-yr-old children associated with asthma risk factors?. Pediatr Allergy Immunol. 2004;15(4):323-30. Excluded because no eligible outcomes presented. [pmid: 15305941].
Longacre AV, Cramer LD, Gross CP. Screening colonoscopy use among individuals at higher colorectal cancer risk. J Clin Gastroenterol. Jul. 2006;40(6):490-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16825930].
Loock M, Steyn K, Becker P, et al. Coronary heart disease and risk factors in Black South Africans: a case-control study. Ethn Dis. 2006;16(4):872-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17061740].
Lopez-Perez G, Morfin-Maciel B, Hernandez T, et al. Prevalence of atopic dermatitis in a group of children in Mexico City. Allergy Clin Immunol Int. 2001;13(6):236-41. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Lorenzo BJ, Hemminki K. Risk of cancer at sites other than the breast in Swedish families eligible for BRCA1 or BRCA2 mutation testing. Ann Oncol. Dec. 2004;15(12):1834-41. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15550590].
Loscalzo ML, Goh DL, Loeys B, et al. Familial thoracic aortic dilation and bicommissural aortic valve: a prospective analysis of natural history and inheritance. Am J Med Genet. Sep. 1. 2007;(Part17):1960-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Lotfi MH, Charkhatti S, Shobairi S. Breast cancer risk factors in an urban area of Yazd city- Iran, 2006. Acta Med Iran. 2008;46(3):258-64. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Low NC, Cui L, Merikangas KR. Specificity of familial transmission of anxiety and comorbid disorders. J Psychiatr Res. Jun. 2008;42(7):596-604. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17706672].
Lowery JT, Byers T, Axell L, et al. The impact of direct-to-consumer marketing of cancer genetic testing on women according to their genetic risk. Genet Med. Dec. 2008;10(12):888-94. Excluded because family history not collected. [pmid: 19092441].
Lubin F, Chetrit A, Freedman LS, et al. Body mass index at age 18 years and during adult life and ovarian cancer risk. Am J Epidemiol. 2003;157(2):113-20. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12522018].
Luby JL, Belden AC, Spitznagel E. Risk factors for preschool depression: The mediating role of early stressful life events. J Child Psychol Psychiatry. 2006;47(12):1292-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17176384].
Ludvigsson JF, Mostrom M, Ludvigsson J, et al. Exclusive breastfeeding and risk of atopic dermatitis in some 8300 infants. Pediatr Allergy Immunol. 2005;16(3):201-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15853948].
Lundback B, Ronmark E, Jonsson E, et al. Incidence of physician-diagnosed asthma in adults - A real incidence or a result of increased awareness? Report from the obstructive lung disease in Northern Sweden studies. Respir Med. 2001;95(8):685-92. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11530958].
Lyketsos CG, Tune LE, Pearlson G, et al. Major depression in Alzheimer's disease. An interaction between gender and family history. Psychosomatics. Jul. 1996;37(4):380-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8701017].
Lynch KL, Ahnen DJ, Byers T, et al. First-degree relatives of patients with advanced colorectal adenomas have an increased prevalence of colorectal cancer. Clin Gastroenterol Hepatol. Mar. 2003;1(2):96-102. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15017501].
Lyssenko V, Almgren P, Anevski D, et al. Predictors of and longitudinal changes in insulin sensitivity and secretion preceding onset of type 2 diabetes. Diabetes. Jan. 2005;54(1):166-74. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15616025].
MacClellan LR, Mitchell BD, Cole JW, et al. Familial aggregation of ischemic stroke in young women: the Stroke Prevention in Young Women Study. Genet Epidemiol. Nov. 2006;30(7):602-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16868965].
MacDonald DJ, Sarna L, Uman GC, et al. Health beliefs of women with and without breast cancer seeking genetic cancer risk assessment. Cancer Nurs 380. Jan. 28(5):372-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
MacDonald DJ, Sarna L, Giger JN, et al. Comparison of Latina and non-Latina white women's beliefs about communicating genetic cancer risk to relatives. J Health Commun. 2008;13(5):465-79. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18661388].
Mack LA, Stuart H, Temple WJ. Survey of colorectal cancer screening practices in a large Canadian urban centre. Can J Surg. Jun. 2004;47(3):189-94. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15264381].
Mackay J, Rogers C, Fielder H, et al. Development of a protocol for evaluation of mammographic surveillance services in women under 50 with a family history of breast cancer. J Epidemiol Biostat 371. May. 6(5):365-9. Excluded because not an eligible study design.
MacLeod HM, McNally EM. A pilot study of a family history risk assessment tool for cardiovascular disease. J Genet Couns. Oct. 2008;17(5):499-507. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18791812].
Macmillan RD. Screening women with a family history of breast cancer--results from the British Familial Breast Cancer Group. Eur J Surg Oncol. Mar. 2000;26(2):149-52. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10744933].
Madlensky L, Esplen MJ, Gallinger S, et al. Relatives of colorectal cancer patients: factors associated with screening behavior. Am J Prev Med. Oct. 2003;25(3):187-94. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14507524].
Madlensky L, Vierkant RA, Vachon CM, et al. Preventive health behaviors and familial breast cancer. Cancer Epidemiol Biomarkers Prev. 2005;14(10):2340-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16214914].
Madlensky L, Flatt SW, Bardwell WA, et al. Is family history related to preventive health behaviors and medical management in breast cancer patients?. Breast Cancer Res Treat. Mar. 2005;90(1):47-54. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15770526].
Magnusson C, Colditz G, Rosner B, et al. Association of family history and other risk factors with breast cancer risk (Sweden). Cancer Causes Control. May. 1998;9(3):259-67. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9684706].
Magura L, Blanchard R, Hope B, et al. Hypercholesterolemia and prostate cancer: a hospital-based case-control study. Cancer Causes Control. Dec. 2008;19(10):1259-66. Excluded because no eligible outcomes presented. [pmid: 18704722].
Mahdavinia M, Bishehsari F, Ansari R, et al. Family history of colorectal cancer in Iran. BMC Cancer. 2005;5:112. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16143045].
Mahouri K, Dehghani ZM, Zare S. Breast cancer risk factors in south of Islamic Republic of Iran: a case-control study. East Mediterr Health J. Nov. 2007;13(6):1265-73. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18341177].
Mainous AG III, Koopman RJ, Diaz VA, et al. A Coronary Heart Disease Risk Score Based on Patient-Reported Information. Am J Cardiol. 2007;99(9):1236-41. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17478150].
Majeed R, Rajar UDM, Shaikh N, et al. Risk factors associated with childhood asthma. J Coll Physicians Surg Pak. 2008;18(5):299-302. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18541086].
Mancuso C, Glendon G, Anson-Cartwright L, et al. Ethnicity, but not cancer family history, is related to response to a population-based mailed questionnaire. Ann Epidemiol. Jan. 2004;14(1):36-43. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14664778].
Mansur ADP, Gomes EPSG, Avakian SD, et al. Clustering of traditional risk factors and precocity of coronary disease in women. Int J Cardiol. 2001;81(2–3):205-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11744138].
Manuel DG, Wilson S, Maaten S. The 2006 Canadian dyslipidemia guidelines will prevent more deaths while treating fewer people - But should they be further modified?. Can J Cardiol. 2008;24(8):617-20. Excluded because family history not collected. [pmid: 18685741].
Marcus GM, Smith LM, Vittinghoff E, et al. A first-degree family history in lone atrial fibrillation patients. Heart Rhythm. 2008;5(6):826-30. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18468961].
Margolin S, Johansson H, Rutqvist LE, et al. Family history, and impact on clinical presentation and prognosis, in a population-based breast cancer cohort from the Stockholm County. Fam Cancer. 2006;5(4):309-21. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16858627].
Marotte JB, Ferrari MK, McNeal JE, et al. Time trends in pathologic features of radical prostatectomy--impact of family history. Urol Oncol. May. 2004;22(3):169-73. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15271309].
Martin W, Degner L. Perception of risk and surveillance practices of women with a family history of breast cancer. Cancer Nurs. May. 2006;29(3):227-35. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16783123].
Martin WL. Perception of risk and surveillance practices for women with a family history of breast cancer. Can Oncol Nurs J. 2003;13(2):131. Excluded because not an eligible study design. [pmid: 12793158].
Marusic A. Factor analysis of risk for coronary heart disease: An independent replication. Int J Cardiol. 2000;75(2–3):233-8. Excluded because no eligible outcomes presented. [pmid: 11077139].
Mastalski K, Coups EJ, Ruth K, et al. Substantial family history of prostate cancer in black men recruited for prostate cancer screening: results from the Prostate Cancer Risk Assessment Program. Cancer. Nov. 1. 2008;113(9):2559-64. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18816608].
Masuo K, Mikami H, Ogihara T, et al. Familial hypertension, insulin, sympathetic activity, and blood pressure elevation. Hypertension. Jul. 1998;32(1):96-100. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9674644].
Matakidou A, Eisen T, Bridle H, et al. Case-control study of familial lung cancer risks in UK women. Int J Cancer. Sep. 1. 2005;116(3):445-50. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15800943].
Matalliotakis IM, Cakmak H, Mahutte N, et al. The familial risk of breast cancer in women with endometriosis from Yale series. Surg Oncol. Dec. 2008;17(4):289-93. Excluded because no eligible outcomes presented. [pmid: 18456491].
Mateo J, Oliver A, Borrell M, et al. Laboratory evaluation and clinical characteristics of 2,132 consecutive unselected patients with venous thromboembolism - Results of the Spanish multicentric study on thrombophilia (EMET-Study). Thromb Haemost. 1997;77(3):444-51. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9065991].
Matsuura N, Fukuda K, Okuno A, et al. Descriptive epidemiology of IDDM in Hokkaido, Japan: The childhood IDDM Hokkaido Registry. Diabetes Care. 1998;21(10):1632-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9773722].
Mavale-Manuel S, Alexandre F, Duarte N, et al. Risk factors for asthma among children in Maputo (Mozambique). Allergy. 2004;59(4):388-93. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15005761].
Mayne ST, Buenconsejo J, Janerich DT. Familial cancer history and lung cancer risk in United States nonsmoking men and women. Cancer Epidemiol Biomarkers Prev. 1999;8(12):1065-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10613338].
McCahy PJ, Harris CA, Neal DE. Breast and prostate cancer in the relatives of men with prostate cancer. Br J Urol. Oct. 1996;78(4):552-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8963638].
McCann S, MacAuley D, Barnett Y. General practitioners and genes: Perceived roles, confidence and satisfaction with knowledge. E J Gen Pract. 2002;8(4):140-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
McCann S, MacAuley D, Barnett Y. Genetic consultations in primary care: GPs' responses to three scenarios. Scand J Prim Health Care. Jun. 2005;23(2):109-14. Excluded because no eligible outcomes presented. [pmid: 16036550].
McClain MR, Palomaki GE, Hampel H, et al. Screen positive rates among six family history screening protocols for breast/ovarian cancer in four cohorts of women. Fam Cancer. 2008;7(4):341-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18297415].
McCredie M, Paul C, Skegg DC, et al. Family history and risk of breast cancer in New Zealand. Int J Cancer. Nov. 14. 1997;73(4):503-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9389563].
McCredie MR, Dite GS, Giles GG, et al. Breast cancer in Australian women under the age of 40. Cancer Causes Control. Mar. 1998;9(2):189-98. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9578296].
McCusker ME, Yoon PW, Gwinn M, et al. Family history of heart disease and cardiovascular disease risk-reducing behaviors. Genet Med. May. 2004;6(3):153-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15354334].
McGrath NM, Parker GN, Dawson P. Early presentation of type 2 diabetes mellitus in young New Zealand Maori. Diabetes Res Clin Pract. 1999;43(3):205-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10369431].
McKinley AG, Russell SE, Spence RA, et al. Hereditary breast cancer in Northern Ireland. Ulster Med J. Nov. 1996;65(2):113-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8979776].
Meeske K, Press M, Patel A, et al. Impact of reproductive factors and lactation on breast carcinoma in situ risk. Int J Cancer. 2004;110(1):102-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15054874].
Mehdipour P, Atri M, Jafarimojarrad E, et al. Laddering through pedigrees: family history of malignancies in primary breast cancer patients. Asian Pac J Cancer Prev. Jul. 2003;4(3):185-92. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14507237].
Melia J, Dearnaley D, Moss S, et al. The feasibility and results of a population-based approach to evaluating prostate-specific antigen screening for prostate cancer in men with a raised familial risk. Br J Cancer. Feb. 27. 2006;94(4):499-506. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16434997].
Mellon S, Gold R, Janisse J, et al. Risk perception and cancer worries in families at increased risk of familial breast/ovarian cancer. Psychooncology. 2008;17(8):756-66. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18613300].
Menon VU, Kumar KV, Gilchrist A, et al. Prevalence of known and undetected diabetes and associated risk factors in central Kerala - ADEPS. Diabetes Res Clin Pract. 2006;74(3):289-94. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16730847].
Menotti A, Giampaoli S. A single risk factor measurement predicts 35-year mortality from cardiovascular disease. G Ital Cardiol. 1998;28(12):1354-62. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9887388].
Menotti A, Lanti M, Maiani G, et al. Forty-year mortality from cardiovascular diseases and their risk factors in men of the Italian rural areas of the Seven Countries Study. Acta Cardiol. 2005;60(5):521-31. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16261784].
Menotti A, Lanti M, Maiani G, et al. Determinants of longevity and all-cause mortality among middle-aged men. Role of 48 personal characteristics in a 40-year follow-up of Italian Rural Areas in the Seven Countries Study. Aging Clin Exp Res. 2006;18(5):394-406. Excluded because no eligible outcomes presented. [pmid: 17167304].
Merchant JA, Naleway AL, Svendsen ER, et al. Asthma and farm exposures in a cohort of rural Iowa children. Environ Health Perspect. 2005;113(3):350-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15743727].
Meschia JF, Case LD, Worrall BB, et al. Family history of stroke and severity of neurologic deficit after stroke. Neurology. Oct. 24. 2006;67(8):1396-402. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17060565].
Mete E, Erdemli K, Bavbek N, et al. High levels of cord serum eosinophil cationic protein predict the risk of atopy. J Asthma. 2004;41(6):679-82. Excluded because no eligible outcomes presented. [pmid: 15584318].
Meunier J, Dorchy H, Luminet O. Does family cohesiveness and parental alexithymia predict glycaemic control in children and adolescents with diabetes?. Diabetes Metab. 2008;34(5):473-81. Excluded because no eligible outcomes presented. [pmid: 18783976].
Meyer P, Zuern C, Hermanns N, et al. The association between paternal prostate cancer and type 2 diabetes. J Carcinog. 2007;6:14. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17897447].
Milionis HJ, Kalantzi KJ, Papathanasiou AJ, et al. Metabolic syndrome and risk of acute coronary syndromes in patients younger than 45 years of age. Coron Artery Dis. 2007;18(4):247-52. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17496487].
Mills PK, Riordan DG, Cress RD. Epithelial ovarian cancer risk by invasiveness and cell type in the Central Valley of California. Gynecol Oncol. 2004;95(1):215-25. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15385135].
Milne BJ, Moffitt TE, Crump R, et al. How should we construct psychiatric family history scores? A comparison of alternative approaches from the Dunedin Family Health History Study. Psychol Med. Dec. 2008;38(12):1793-802. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18366822].
Minami Y, Ohuchi N, Fukao A, et al. Risk factors for breast cancer: A case-control study of screen-detected breast cancer in Miyagi Prefecture, Japan. Breast Cancer Res Treat. 1997;44(3):225-33. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9266102].
Mink PJ, Folsom AR, Sellers TA, et al. Physical activity, waist-to-hip ratio, and other risk factors for ovarian cancer: a follow-up study of older women. Epidemiology. Jan. 1996;7(1):38-45. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8664399].
Mirzaei F, Kazemi N. Prevalence of polycystic ovary syndrome in women with type 2 diabetes in Kerman, Iran. Metab Syndr Relat Disord. 2008;6(3):215-7. Excluded because no eligible outcomes presented. [pmid: 18710333].
Mitchell BD, Zaccaro D, Wagenknecht LE, et al. Insulin sensitivity, body fat distribution, and family diabetes history: the IRAS Family Study. Obes Res. May. 2004;12(5):831-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15166304].
Mitsunobu F, Mifune T, Hosaki Y, et al. IgE-mediated and age-related bronchial hyperresponsiveness in patients with asthma. Relationship to family history of the disease. Age Ageing. May. 2000;29(3):215-20. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10855902].
Miyake Y, Tanaka K, Sasaki S, et al. Breastfeeding and the risk of wheeze and asthma in Japanese infants: The Osaka Maternal and Child Health Study. Pediatr Allergy Immunol. 2008;19(6):490-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18266830].
Modugno F, Ness RB, Wheeler JE. Reproductive risk factors for epithelial ovarian cancer according to histologic type and invasiveness. Ann Epidemiol. 2001;11(8):568-74. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11709277].
Molino A, Giovannini M, Pedersini R, et al. Correlations between family history and cancer characteristics in 2256 breast cancer patients. Br J Cancer. Jul. 5. 2004;91(1):96-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15162141].
Moller P, Reis MM, Evans G, et al. Efficacy of early diagnosis and treatment in women with a family history of breast cancer. European Familial Breast Cancer Collaborative Group. Dis Markers. Oct. 1999;15(1–3):179-86. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10595275].
Molyneaux L, Constantino M, Yue D. Strong family history predicts a younger age of onset for subjects diagnosed with type 2 diabetes. Diabetes Obes Metab. May. 2004;6(3):187-94. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15056126].
Momiyama Y, Suzuki Y, Ohsuzu F, et al. Maternally transmitted susceptibility to non-insulin-dependent diabetes mellitus and left ventricular hypertrophy. J Am Coll Cardiol. Apr. 1999;33(5):1372-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10193741].
Montefort S, Lenicker HM, Caruna S, et al. Asthma, rhinitis and eczema in Maltese 13–15 year-old schoolchildren - Prevalence, severity and associated factors [ISAAC]. Clin Exp Allergy. 1998;28(9):1089-99. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9761012].
Montefort S, Muscat HA, Caruana S, et al. Allergic conditions in 5–8-year-old Maltese schoolchildren: Prevalence, severity, and associated risk factors [ISAAC]. Pediatr Allergy Immunol. 2002;13(2):98-104. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12000481].
Monti MC, Lonsdale JT, Montomoli C, et al. Familial risk factors for microvascular complications and differential male-female risk in a large cohort of American families with type 1 diabetes. J Clin Endocrinol Metab. Dec. 2007;92(12):4650-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17878250].
Montnemery P, Adelroth E, Heuman K, et al. Prevalence of obstructive lung diseases and respiratory symptoms in southern Sweden. Respir Med. 1998;92(12):1337-45. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10197227].
Moore MM, Rifas-Shiman SL, Rich-Edwards JW, et al. Perinatal Predictors of Atopic Dermatitis Occurring in the First Six Months of Life. Pediatrics. 2004;113(3 I):468-74. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14993536].
Mooy JM, Grootenhuis PA, de Vries H, et al. Prevalence and determinants of glucose intolerance in a Dutch Caucasian population: The Hoorn study. Diabetes Care. 1995;18(9):1270-3. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8612442].
Mori M, Nishida T, Sugiyama T, et al. Anthropometric and other risk factors for ovarian cancer in a case-control study. Jpn J Cancer Res. Mar. 1998;89(3):246-53. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9600117].
Morris L, Taylor M, Campbell LM, et al. How will practices cope with information for the new GMS contract? Coronary heart disease data recording in five Scottish practices. Inform Prim Care. 2003;11(3):121-7. Excluded because no eligible outcomes presented. [pmid: 14680534].
Morris MC, Ciesla JA, Garber J. A prospective study of the cognitive-stress model of depressive symptoms in adolescents. J Abnorm Psychol. Nov. 2008;117(4):719-34. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 19025221].
Morrison JA, Friedman LA, Wang P, et al. Metabolic Syndrome in Childhood Predicts Adult Metabolic Syndrome and Type 2 Diabetes Mellitus 25 to 30 Years Later. J Pediatr. 2008;152(2):201-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18206689].
Moses R, Rodda M, Griffiths R. Predominance of a maternal history of diabetes for patients with non-insulin-independent diabetes mellitus. Implications for the intrauterine transmission of diabetes. Aust N Z J Obstet Gynaecol. 1997;37(3):279-81. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9325504].
Moskowitz WB, Schwartz PF, Schieken RM. Childhood passive smoking, race, and coronary artery disease risk: The MCV twin study. Arch Pediatr Adolesc Med. 1999;153(5):446-53. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10323623].
Mouchawar J, Klein CE, Mullineaux L. Colorado family physicians' knowledge of hereditary breast cancer and related practice. J Cancer Educ. 2001;16(1):33-7. Excluded because family history not collected. [pmid: 11270897].
Mourad M, Levendosky A, Bogat GA, et al. Family psychopathology and perceived stress of both domestic violence and negative life events as predictors of women's mental health symptoms. J Fam Violence. Nov. 2008;23(8):661-70. Excluded because not an eligible population.
Moussa MAA, Alsaeid M, Refai TMK, et al. Factors associated with type 1 diabetes in Kuwaiti children. Acta Diabetol. 2005;42(3):129-37. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16258736].
Moussa MAA, Alsaeid M, Abdella N, et al. Prevalence of type 2 diabetes mellitus among Kuwaiti children and adolescents. Med Princ Pract. 2008;17(4):270-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18523392].
Mrena S, Virtanen SM, Laippala P, et al. Models for predicting type 1 diabetes in siblings of affected children. Diabetes Care. Mar. 2006;29(3):662-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16505523].
Murff HJ, Byrne D, Syngal S. Cancer risk assessment: quality and impact of the family history interview. Am J Prev Med. Oct. 2004;27(3):239-45. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15450637].
Murff HJ, Peterson NB, Greevy R, et al. Impact of patient age on family cancer history. Genet Med. Jul. 2006;8(7):438-42. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16845276].
Murff HJ, Greevy RA, Syngal S. The comprehensiveness of family cancer history assessments in primary care. Community Genet. 2007;10(3):174-80. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17575462].
Murgia C, Berria R, Minerba L, et al. Risk assessment does not explain high prevalence of gestational diabetes mellitus in a large group of Sardinian women. Reprod Biol Endocrinol. 2008;6:26. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18593483].
Mursu J, Voutilainen S, Nurmi T, et al. Flavonoid intake and the risk of ischaemic stroke and CVD mortality in middle-aged Finnish men: The Kuopio Ischaemic Heart Disease Risk Factor Study. Br J Nutr. 2008;100(4):890-5. Excluded because no eligible outcomes presented. [pmid: 18377681].
Murta-Nascimento C, Silverman DT, Kogevinas M, et al. Risk of bladder cancer associated with family history of cancer: do low-penetrance polymorphisms account for the increase in risk?. Cancer Epidemiol Biomarkers Prev. Aug. 2007;16(8):1595-600. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17684133].
Myers CD, Jacobsen PB, Huang Y, et al. Familial and perceived risk of breast cancer in relation to use of complementary medicine. Cancer Epidemiol Biomarkers Prev. 2008;17(6):1527-34. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18541615].
Naff JL, Cote ML, Wenzlaff AS, et al. Racial differences in cancer risk among relatives of patients with early onset lung cancer. Chest. May. 2007;131(5):1289-94. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17400658].
Naheed F, Kammeruddin K, Hashmi HA, et al. Frequency of impaired oral glucose tolerance test in high risk pregnancies for gestational diabetes mellitus. J Coll Physicians Surg Pak. 2008;18(2):82-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18454891].
Nakama H, Zhang B, Fukazawa K, et al. Family history of colorectal adenomatous polyps as a risk factor for colorectal cancer. Eur J Cancer. Oct. 2000;36(16):2111-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11044649].
Nakama H, Fukazawa K. Colorectal cancer risk in first-degree relatives of patients with colorectal adenomatous polyp. Hepatogastroenterology. Jan. 2002;49(43):157-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11941942].
Nam RK, Toi A, Klotz LH, et al. Assessing individual risk for prostate cancer. J Clin Oncol. 2007;25(24):3582-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17704405].
Nandkeoliar MK, Dharmalingam M, Marcus SR. Diabetes mellitus in Asian Indian children and adolescents. J Pediatr Endocrinol Metab. 2007;20(10):1109-14. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18051929].
Nasir K, Michos ED, Rumberger JA, et al. Coronary artery calcification and family history of premature coronary heart disease: sibling history is more strongly associated than parental history. Circulation. Oct. 12. 2004;110(15):2150-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15466626].
Nasir K, Budoff MJ, Wong ND, et al. Family history of premature coronary heart disease and coronary artery calcification: Multi-Ethnic Study of Atherosclerosis (MESA). Circulation. Aug. 7. 2007;116(6):619-26. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17646582].
Negri E, Braga C, La Vecchia C, et al. Family history of cancer and risk of breast cancer. Int J Cancer. Sep. 4. 1997;72(5):735-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9311586].
Negri E, Braga C, La Vecchia C, et al. Family history of cancer and risk of colorectal cancer in Italy. Br J Cancer. 1998;77(1):174-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9459165].
Negri E, Pelucchi C, Franceschi S, et al. Family history of cancer and risk of ovarian cancer. Eur J Cancer. Mar. 2003;39(4):505-10. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12751382].
Negri E, Pelucchi C, Talamini R, et al. Family history of cancer and the risk of prostate cancer and benign prostatic hyperplasia. Int J Cancer. Apr. 20. 2005;114(4):648-52. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15578689].
Negri E, Foschi R, Talamini R, et al. Family history of cancer and the risk of renal cell cancer. Cancer Epidemiol Biomarkers Prev. Dec. 2006;15(12):2441-4. Excluded because no eligible outcomes presented. [pmid: 17164368].
Neise C, Rauchfuss M, Paepke S, et al. Risk perception and psychological strain in women with a family history of breast cancer. Onkologie. Oct. 2001;24(5):470-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11694774].
Nelson T, Perez A, Alcaraz J, et al. Family history of diabetes, acculturation, and the metabolic syndrome among Mexican Americans: Proyecto SALSA. Metab Syndr Relat Disord. 2007;5(3):262-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18370780].
Nemesure B, Wu SY, Hambleton IR, et al. Risk factors for breast cancer in a black population--the Barbados National Cancer Study. Int J Cancer. Jan. 1. 2009;124(1):174-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18814239].
Ness RB, Markovic N, Bass D, et al. Family history of hypertension, heart disease, and stroke among women who develop hypertension in pregnancy. Obstet Gynecol. Dec. 2003;102(6):1366-71. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14662228].
Newcomb PA, Taylor JO, Trentham-Dietz A. Interactions of familial and hormonal risk factors for large bowel cancer in women. Int J Epidemiol. Aug. 1999;28(4):603-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10480684].
Nicolaou M, DeStefano AL, Gavras I, et al. Genetic predisposition to stroke in relatives of hypertensives. Stroke. Feb. 2000;31(2):487-92. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10657427].
Nilsson PM, Nilsson J-A, Berglund G. Family burden of cardiovascular mortality: Risk implications for offspring in a national register linkage study based upon the Malmo Preventive Project. J Intern Med. 2004;255(2):229-35. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14746560].
Nishigaki M, Kobayashi K, Hitomi T, et al. Perception of offspring risk for type 2 diabetes among patients with type 2 diabetes and their adult offspring. Diabetes Care. 2007;30(12):3033-4. Excluded because no eligible outcomes presented. [pmid: 17804684].
Nishigaki M, Kobayashi K, Kato N, et al. Preventive advice given by patients with type 2 diabetes to their offspring. Br J Gen Pract. Jan. 2009;59(558):37-42. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 19105914].
Nishtar S, Wierzbicki AS, Lumb PJ, et al. Waist-hip ratio and low HDL predict the risk of coronary artery disease in Pakistanis. Curr Med Res Opin. 2004;20(1):55-62. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14741073].
Nitadori J, Inoue M, Iwasaki M, et al. Association between lung cancer incidence and family history of lung cancer: data from a large-scale population-based cohort study, the JPHC study. Chest. Oct. 2006;130(4):968-75. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17035426].
Nixon RM, Pharoah P, Tabar L, et al. Mammographic screening in women with a family history of breast cancer: some results from the Swedish two-county trial. Rev Epidemiol Sante Publique. Aug. 2000;48(4):325-31. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11011299].
No ai. Promoting physical activity in an at-risk population. J Sport Exerc Psychol. Jun. 2008;30(3):434. Excluded because not an eligible study design.
Norman P, Brain K. An application of an extended health belief model to the prediction of breast self-examination among women with a family history of breast cancer. Br J Health Psychol. Feb. 2005;10(Pt:1):1-16. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15826330].
Norrman E, Nystrom L, Jonsson E, et al. Prevalence and incidence of asthma and rhinoconjunctivitis in Swedish teenagers. Allergy. Jan. 1998;53(1):28-35. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Norsa'adah B, Rusli BN, Imran AK, et al. Risk factors of breast cancer in women in Kelantan, Malaysia. Singapore Med J. Dec. 2005;46(12):698-705. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16308643].
Nuhu FT, Odejide OA, Adebayo KO, et al. Prevalence and predictors of depression in cancer patients in the University College Hospital Ibadan, Nigeria. Hong Kong J Psychiatry. 2008;18(3):107-14. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Nwose EU, Richards RS, Kerr PG, et al. Oxidative damage indices for the assessment of subclinical diabetic macrovascular complications. Br J Biomed Sci. 2008;65(3):136-41. Excluded because no eligible outcomes presented. [pmid: 18986101].
O'Neil JN, Emery CF. Psychosocial vulnerability, hostility, and family history of coronary heart disease among male and female college students. Int J Behav Med. 2002;9(1):17-36. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12112994].
O'Sullivan B, McGee H, Keegan O. Comparing solutions to the 'expectancy-value muddle' in the theory of planned behaviour. Br J Health Psychol. 2008;13(4):789-802. Excluded because family history not collected. [pmid: 18215337].
Ockhuysen-Vermey CF, Henneman L, van Asperen CJ, et al. Design of the BRISC study: A multicentre controlled clinical trial to optimize the communication of breast cancer risks in genetic counselling. BMC Cancer. 2008;8:283. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18834503].
Ogonowski J, Miazgowski T, Homa K, et al. Low predictive value of traditional risk factors in identifying women at risk for gestational diabetes. Acta Obstet Gynecol Scand. 2007;86(10):1165-70. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Ohaeri JU, Otote DI. Family history, life events and the factorial structure of depression in a Nigerian sample of inpatients. Psychopathology. Jul. 2002;35(4):210-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12239437].
Ohannessian CM, Hesselbrock VM. Predictors of substance abuse and affective diagnosis: Does having a family history of alcoholism make a difference?. Appl Dev Sci. 1999;3(4):239-47. Excluded because no eligible outcomes presented.
Okamoto K, Horisawa R, Kawamura T, et al. Family history and risk of subarachnoid hemorrhage: a case-control study in Nagoya, Japan. Stroke. Feb. 2003;34(2):422-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12574554].
Oldak E, Kurzatkowska B, Stasiak-Barmuta A. Natural course of sensitization in children: follow-up study from birth to 6 years of age, I. Evaluation of total serum IgE and specific IgE antibodies with regard to atopic family history. Rocz Akad Med Bialymst. 2000;45:87-95. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11712445].
Olesen AB, Ellingsen AR, Olesen H, et al. Atopic dermatitis and birth factors: historical follow up by record linkage. BMJ. Apr. 5. 1997;314(7086):1003-8. Excluded because no eligible outcomes presented. [pmid: 9112844].
Oleske DM, Galvez A, Cobleigh MA, et al. Are tri-ethnic low-income women with breast cancer effective teachers of the importance of breast cancer screening to their first-degree relatives? Results from a randomized clinical trial. Breast J. Jan. 2007;13(1):19-27. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17214789].
Oliveira JEP, Milech A, Franco LJ. The prevalence of diabetes in Rio de Janeiro, Brazil. Diabetes Care. 1996;19(6):663-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8725870].
Olson JE, Sellers TA, Iturria SJ, et al. Bilateral oophorectomy and breast cancer risk reduction among women with a family history. Cancer Detect Prev. 2004;28(5):357-60. Excluded because family history not collected Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15542261].
Olsson H, Bladstrom A. A cohort study of reproductive factors and family history of breast cancer in southern Sweden. Breast Cancer Res Treat. Dec. 2002;76(3):203-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12462381].
Omar MA, Motala AA, Seedat MA, et al. The significance of a positive family history in South African Indians with non-insulin-dependent diabetes (NIDDM). Diabetes Res Clin Pract. Oct. 1996;34:S13-S16. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9015665].
Omland O, Sigsgaard T, Hjort C, et al. Lung status in young Danish rurals: The effect of farming exposure on asthma-like symptoms and lung function. Eur Respir J. 1999;13(1):31-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10836319].
Orom H, Cote ML, Gonzalez HM, et al. Family history of cancer: is it an accurate indicator of cancer risk in the immigrant population?. Cancer. Jan. 15. 2008;112(2):399-406. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18072272].
Othmer E, DeSouza CM, Penick EC, et al. Indicators of mania in depressed outpatients: A retrospective analysis of data from the Kansas 1500 study. J Clin Psychiatry. 2007;68(1):47-51. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17284129].
Ott C, Obermeier F, Thieler S, et al. The incidence of inflammatory bowel disease in a rural region of Southern Germany: a prospective population-based study. Eur J Gastroenterol Hepatol. Sep. 2008;20(9):917-23. Excluded because no eligible outcomes presented. [pmid: 18794607].
Ozaki R, Qiao Q, Wong GW, et al. Overweight, family history of diabetes and attending schools of lower academic grading are independent predictors for metabolic syndrome in Hong Kong Chinese adolescents. Arch Dis Child. Mar. 2007;92(3):224-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17088339].
Paek KW, Chun KH, Lee KW. Relationship between metabolic syndrome and familial history of hypertension/stroke, diabetes, and cardiovascular disease. J Korean Med Sci. Aug. 2006;21(4):701-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16891816].
Page WF, Braun MM, Partin AW, et al. Heredity and prostate cancer: A study of world war II veteran twins. Prostate. 1997;33(4):240-5. Excluded because family history not collected. [pmid: 9397195].
Pakhale S, Wooldrage K, Manfreda J, et al. Prevalence of asthma symptoms in 7th- and 8th-grade school children in a rural region in India. J Asthma. 2008;45(2):117-22. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18350403].
Pal T, Vadaparampil S, Betts J, et al. BRCA1/2 in high-risk African American women with breast cancer: Providing genetic testing through various recruitment strategies. Genet Test. 2008;12(3):401-7. Excluded because no eligible outcomes presented. [pmid: 18752448].
Pala K, Aksu H. Prevalence and associated risk factors of type 2 diabetes mellitus in Nilufer District, Bursa, Turkey. Int J Diabetes Metabol. 2006;14(2):98-102. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Pallasaho P, Lundback B, Laspa SL, et al. Increasing prevalence of asthma but not of chronic bronchitis in Finland? Report from the FinEsS-Helsinki study. Respir Med. 1999;93(11):798-809. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10603629].
Palomaki GE, McClain MR, Steinort K, et al. Screen-positive rates and agreement among six family history screening protocols for breast/ovarian cancer in a population-based cohort of 21- to 55-year-old women. Genet Med. Mar. 2006;8(3):161-8. Excluded because no eligible outcomes presented. [pmid: 16540750].
Panagiotakos DB, Pitsavos C, Chrysohoou C, et al. Risk stratification of coronary heart disease in Greece: Final results from the CARDIO2000 epidemiological study. Prev Med. 2002;35(6):548-56. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12460522].
Panagiotakos DB, Pitsavos C, Chrysohoou C, et al. An integrated assessment of family history on the risk of developing acute coronary syndromes (CARDIO2000 study). Acta Cardiol. Aug. 2004;59(4):383-90. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15368799].
Panagiotakos DB, Pitsavos C, Skoumas Y, et al. Five-year incidence of type 2 diabetes mellitus among cardiovascular disease-free Greek adults: Findings from the ATTICA study. Vasc Health Risk Manag. 2008;4(3):691-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18827919].
Panagiotakos DB, Pitsavos C, Chrysohoou C, et al. Hierarchical analysis of cardiovascular risk factors in relation to the development of acute coronary syndromes, in different parts of Greece: The CARDIO2000 study. Angiology. 2008;59(2):156-65. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18388034].
Panagiotakos DB, Pitsavos C, Skoumas Y, et al. Five-year incidence of type 2 diabetes mellitus among cardiovascular disease-free Greek adults: Findings from the ATTICA study. Vasc Health Risk Manag. 2008;4(3):691-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18827919].
Panikar VK, Joshi SR, Kakraniya P, et al. Inter-generation comparison of type-2 diabetes in 73 Indian families. J Assoc Physicians India. Aug. 2008;56:601-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 19051704].
Pannacciulli N, De Pergola G, Ciccone M, et al. Effect of family history of type 2 diabetes on the intima-media thickness of the common carotid artery in normal-weight, overweight, and obese glucose-tolerant young adults. Diabetes Care. Apr. 2003;26(4):1230-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12663602].
Parent ME, Ghadirian P, Lacroix A, et al. The reliability of recollections of family history: implications for the medical provider. J Cancer Educ. 1997;12(2):114-20. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9229275].
Parikh NI, Hwang SJ, Larson MG, et al. Parental occurrence of premature cardiovascular disease predicts increased coronary artery and abdominal aortic calcification in the Framingham Offspring and Third Generation cohorts. Circulation. Sep. 25. 2007;116(13):1473-81. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17785619].
Parikh NI, Hwang SJ, Yang Q, et al. Clinical correlates and heritability of cystatin C (from the Framingham Offspring Study). Am J Cardiol. Nov. 1. 2008;102(9):1194-8. Excluded because family history not collected. [pmid: 18940290].
Park HS, Kim SM, Lee JS, et al. Prevalence and trends of metabolic syndrome in Korea: Korean National Health and Nutrition Survey 1998–2001. Diabetes Obes Metab. 2007;9(1):50-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17199718].
Park JW, Yun JE, Park T, et al. Family history of diabetes and risk of atherosclerotic cardiovascular disease in Korean men and women. Atherosclerosis. Mar. 2008;197(1):224-31. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17493625].
Partin MR, Burgess DJ, Halek K, et al. Randomized trial showed requesting medical records with a survey produced a more representative sample than requesting separately. J Clin Epidemiol. 2008;61(10):1028-35. Excluded because no eligible outcomes presented. [pmid: 18550333].
Parvez T, Anwar MS, Sheikh AM. Study of risk factors for carcinoma breast in adult female general population in Lahore. J Coll Physicians Surg Pak. 2001;11(5):291-3. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Pascale RW, Wing RR, Butler BA, et al. Effects of a behavioral weight loss program stressing calorie restriction versus calorie plus fat restriction in obese individuals with NIDDM or a family history of diabetes. Diabetes Care. Sep. 1995;18(9):1241-8. Excluded because no eligible outcomes presented. [pmid: 8612437].
Pasquarella A, Buonomo E, Carbini R, et al. Family history of cardiovascular diseases and risk factors in children. J Hum Hypertens. Sep. 1996;10(Suppl 3):S107-109. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8872839].
Patel MJ, de Lemos JA, Philips B, et al. Implications of family history of myocardial infarction in young women. Am Heart J. Sep. 2007;154(3):454-60. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17719289].
Patenaude AF, Orozco S, Li X, et al. Support needs and acceptability of psychological and peer consultation: Attitudes of 108 women who had undergone or were considering prophylactic mastectomy. Psychooncology. Aug. 2008;17(8):831-43. Excluded because no eligible outcomes presented. [pmid: 18636423].
Pazarloglou M, Spaia S, Pagkalos E, et al. Evaluation of insulin resistance and sodium sensitivity in normotensive offspring of hypertensive individuals. Am J Kidney Dis. Apr. 2007;49(4):540-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17386322].
Pearson JD, Lei HH, Beaty TH, et al. Familial aggregation of bothersome benign prostatic hyperplasia symptoms. Urology. Apr. 2003;61(4):781-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12670565].
Pelucchi C, Galeone C, Talamini R, et al. Lifetime ovulatory cycles and ovarian cancer risk in 2 Italian case-control studies. Am J Obstet Gynecol. 2007;196(1):83. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17240246].
Pereira MA, Schreiner PJ, Pankow JS, et al. The Family Risk Score for coronary heart disease: associations with lipids, lipoproteins, and body habitus in a middle-aged bi-racial cohort: The ARIC study. Ann Epidemiol. May. 2000;10(4):239-45. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10917717].
Pereira MU, Sly PD, Pitrez PM, et al. Nonatopic asthma is associated with helminth infections and bronchiolitis in poor children. Eur Respir J. 2007;29(6):1154-60. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17331964].
Perez LH, Gutierrez LA, Vioque J, et al. Relation between overweight, diabetes, stress and hypertension: A case-control study in Yarumal - Antioquia, Colombia. Eur J Epidemiol. 2001;17(3):275-80. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11680548].
Perlis RH, Brown E, Baker RW, et al. Clinical features of bipolar depression versus major depressive disorder in large multicenter trials. Am J Psychiatry. 2006;163(2):225-31. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16449475].
Pesonen M, Kallio MJT, Ranki A, et al. Prolonged exclusive breastfeeding is associated with increased atopic dermatitis: A prospective follow-up study of unselected healthy newborns from birth to age 20 years. Clin Exp Allergy. 2006;36(8):1011-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16911357].
Peters CA, Stock RG, Blacksburg SR, et al. Effect of family history on outcomes in patients treated with definitive brachytherapy for clinically localized prostate cancer. Int J Radiat Oncol Biol Phys. Jan. 1. 2009;73(1):24-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18692325].
Petersen GM, Larkin E, Codori AM, et al. Attitudes toward colon cancer gene testing: survey of relatives of colon cancer patients. Cancer Epidemiol Biomarkers Prev. Apr. 1999;8(4:Pt 2):337-44. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10207638].
Petrisek A, Campbell S, Laliberte L. Family history of breast cancer: impact on the disease experience. Cancer Pract. May. 2000;8(3):135-42. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11898138].
Pharoah PD, Lipscombe JM, Redman KL, et al. Familial predisposition to breast cancer in a British population: implications for prevention. Eur J Cancer. Apr. 2000;36(6):773-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10762751].
Philips B, de Lemos JA, Patel MJ, et al. Relation of family history of myocardial infarction and the presence of coronary arterial calcium in various age and risk factor groups. Am J Cardiol. Mar. 15. 2007;99(6):825-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17350375].
Phillips KA, Butow PN, Stewart AE, et al. Predictors of participation in clinical and psychosocial follow-up of the kConFab breast cancer family cohort. Fam Cancer. 2005;4(2):105-13. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15951960].
Phillips KL, An P, Boyd JH, et al. Major gene effect and additive familial pattern of inheritance of asthma exist among families of probands with sickle cell anemia and asthma. Am J Human Biol. Mar. 2008;20(2):149-53. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18161041].
Pierce M, Harding D, Ridout D, et al. Risk and prevention of type II diabetes: offspring's views. Br J Gen Pract. Mar. 2001;51(464):194-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11255900].
Pinol V, Andreu M, Castells A, et al. Synchronous colorectal neoplasms in patients with colorectal cancer: predisposing individual and familial factors. Dis Colon Rectum. Jul. 2004;47(7):1192-200. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15164252].
Piver MS, Goldberg JM, Tsukada Y, et al. Characteristics of familial ovarian cancer: a report of the first 1,000 families in the Gilda Radner Familial Ovarian Cancer Registry. Eur J Gynaecol Oncol. 1996;17(3):169-76. Excluded because no eligible outcomes presented. [pmid: 8780913].
Pohjola-Sintonen S, Rissanen A, Liskola P, et al. Family history as a risk factor of coronary heart disease in patients under 60 years of age. Eur Heart J. Feb. 1998;19(2):235-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9519316].
Polednak AP, Flannery JT. Family history of breast and ovarian cancer among breast-cancer patients in the Connecticut Tumor Registry. Conn Med. Feb. 1996;60(2):67-73. Excluded because no eligible outcomes presented. [pmid: 8820629].
Polley BA, Jakicic JM, Venditti EM, et al. The effects of health beliefs on weight loss in individuals at high risk for NIDDM. Diabetes Care. 1997;20(10):1533-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9314630].
Polosa R, Al Delaimy WK, Russo C, et al. Greater risk of incident asthma cases in adults with allergic rhinitis and effect of allergen immunotherapy: A retrospective cohort study. Respir Res. Dec. 28. 2005;6:153. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16381607].
Polychronopoulos P, Gioldasis G, Ellul J, et al. Family history of stroke in stroke types and subtypes. J Neurol Sci. Mar. 30. 2002;195(2):117-22. Excluded because not an eligible population. [pmid: 11897241].
Ponder M, Lee J, Green J, et al. Family history and perceived vulnerability to some common diseases: A study of young people and their parents. J Med Genet. 1996;33(6):485-92. Excluded because no eligible outcomes presented. [pmid: 8782049].
Poole CA, Byers T, Calle EE, et al. Influence of a family history of cancer within and across multiple sites on patterns of cancer mortality risk for women. Am J Epidemiol. 1999;149(5):454-62. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10067905].
Portengen L, Sigsgaard T, Omland O, et al. Low prevalence of atopy in young danish farmers and farming students born and raised on a farm. Clin Exp Allergy. 2002;32(2):247-53. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11929489].
Pottier P, Cormier G, Truchaud F, et al. Efficiency of systematic thrombophilia screening in idiopathic venous thrombosis: A prospective study in internal medicine. Clin Appl Thromb Hemost. 2005;11(3):243-51. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16015409].
Pratt CA, Ha L, Levine SR, et al. Stroke Knowledge and Barriers to Stroke Prevention Among African Americans: Implications for Health Communication. J Health Commun. Jul. 2003;8(4):369-81. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12907401].
Pravin D, Malhotra S, Chakrabarti S, et al. Frequency of major affective disorders in first-degree relatives of patients with type 2 diabetes mellitus. Indian J Med Res. Sep. 2006;124(3):291-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17085832].
Purdie D, Green A, Bain C, et al. Reproductive and other factors and risk of epithelial ovarian cancer: an Australian case-control study. Survey of Women's Health Study Group. Int J Cancer. Sep. 15. 1995;62(6):678-84. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 7558414].
Purvis DJ, Thompson JM, Clark PM, et al. Risk factors for atopic dermatitis in New Zealand children at 3.5 years of age. Br J Dermatol. Apr. 2005;152(4):742-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15840107].
Quillin JM, Ramakrishnan V, Borzelleca J, et al. Paternal relatives and family history of breast cancer. Am J Prev Med. Sep. 2006;31(3):265-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16905040].
Quillin JM, Bodurtha JN, McClish DK, et al. The effect of a school-based educational intervention on gender differences in reported family cancer history. J Cancer Educ. 2008;23(3):180-5. Excluded because no eligible outcomes presented. [pmid: 18709590].
Quillin JM, Silberg J, Jones RM, et al. Tolerance for ambiguity could influence awareness of breast cancer genetic testing and inform health education. Cancer Causes Control. Dec. 2008;19(10):1227-32. Excluded because no eligible outcomes presented. [pmid: 18592383].
Qureshi N, Kai J. Informing patients of familial diabetes mellitus risk: How do they respond? A cross-sectional survey. BMC Health Serv Res. 2008;8:37. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18257922].
Raby BA, Van Steen K, Celedon JC, et al. Paternal history of asthma and airway responsiveness in children with asthma. Am J Respir Crit Care Med. Sep. 1. 2005;172(5):552-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15937295].
Rader JS, Neuman RJ, Brady J, et al. Cancer among first-degree relatives of probands with invasive and borderline ovarian cancer. Obstet Gynecol. Oct. 1998;92(4:Pt 1):589-595. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9764634].
Radzikowska E, Roszkowski K, Glaz P. Lung cancer in patients under 50 years old. Lung Cancer. 2001;33(2–3):203-11. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11551415].
Rafter N, Wells S, Stewart A, et al. Gaps in primary care documentation of cardiovascular risk factors. N Z Med J. 2008;121(1269):24-33. Excluded because no eligible outcomes presented. [pmid: 18278079].
Ram R, Goswami DN, Bhattacharya SK, et al. An epidemiological study on risk factors of diabetes mellitus among patients attending a Medical College Hospital in Kolkata, West Bengal. J Indian Med Assoc. 2006;104(8):428-30. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17240798].
Ramachandran A, Snehalatha C, Mukesh B, et al. Persistent impaired glucose tolerance has similar rate of risk factors as for diabetes-Results of Indian Diabetes Prevention Programme (IDPP). Diabetes Res Clin Pract. 2006;73(1):100-3. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16406189].
Ramachandran A, Mary S, Yamuna A, et al. High prevalence of diabetes and cardiovascular risk factors associated with urbanization in India. Diabetes Care. May. 2008;31(5):893-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18310309].
Ramji F, Cotterchio M, Manno M, et al. Association between subject factors and colorectal cancer screening participation in Ontario, Canada. Cancer Detect Prev. 2005;29(3):221-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15896925].
Ramsey SD, Clarke L, Etzioni R, et al. Cost-effectiveness of microsatellite instability screening as a method for detecting hereditary nonpolyposis colorectal cancer. Ann Intern Med. Oct. 16. 2001;135(8:Pt 1):577-88. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11601929].
Ramsey SD, Burke W, Pinsky L, et al. Family history assessment to detect increased risk for colorectal cancer: conceptual considerations and a preliminary economic analysis. Cancer Epidemiol Biomarkers Prev. Nov. 2005;14(11:Pt 1):2494-2500. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16284369].
Randi G, Pelucchi C, Negri E, et al. Family history of urogenital cancers in patients with bladder, renal cell and prostate cancers. Int J Cancer. Dec. 15. 2007;121(12):2748-52. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17724720].
Ranjith N, Verho NK, Verho M, et al. Acute myocardial infarction in a young South African Indian-based population: Patient characteristics on admission and gender-specific risk factor prevalence. Curr Med Res Opin. 2002;18(4):242-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12201626].
Ranjith N, Pegoraro RJ, Naidoo DP. Demographic data and outcome of acute coronary syndrome in the South African Asian Indian population. Cardiovasc J S Afr. 2005;16(1):48-54. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15578115].
Rankow EJ, Tessaro I. Mammography and risk factors for breast cancer in lesbian and bisexual women. Am J Health Behav. Nov. 1998;22(6):403-10. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Rasouli N, Spencer HJ, Rashidi AA, et al. Impact of family history of diabetes and ethnicity on -cell function in obese, glucose-tolerant individuals. J Clin Endocrinol Metab. Dec. 2007;92(12):4656-63. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17878257].
Rauscher GH, Sandler DP. Validating cancer histories in deceased relatives. Epidemiology. Mar. 2005;16(2):262-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15703544].
Rawal R, Bertelsen L, Olsen JH. Cancer incidence in first-degree relatives of a population-based set of cases of early-onset breast cancer. Eur J Cancer. Nov. 2006;42(17):3034-40. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16996259].
Rawl SM, Champion VL, Scott LL, et al. A randomized trial of two print interventions to increase colon cancer screening among first-degree relatives. Patient Educ Couns. 2008;71(2):215-27. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18308500].
Rebbeck TR, Turner ST, Sing CF. Probability of having hypertension: Effects of sex, history of hypertension in parents, and other risk factors. J Clin Epidemiol. 1996;49(7):727-34. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8691221].
Reed T, Carmelli D, Swan GE, et al. Ten-year follow-up for male twins divided into high- or low-risk groups for ischemic heart disease based on risk factors measured 25 years previously. Ann Epidemiol. 2000;10(5):278-84. Excluded because no eligible outcomes presented. [pmid: 10942875].
Reinherz HZ, Giaconia RM, Hauf AMC, et al. General and specific childhood risk factors for depression and drug disorders by early adulthood. J Am Academy Child Adolesc Psychiatry. Feb. 2000;39(2):223-31. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Rende R, Birmaher B, Axelson D, et al. Psychotic symptoms in pediatric bipolar disorder and family history of psychiatric illness. J Affect Disord. Nov. 2006;96(1–2):127-31. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16814395].
Retnakaran R, Connelly PW, Sermer M, et al. The impact of family history of diabetes on risk factors for gestational diabetes. Clin Endocrinol (Oxf). Nov. 2007;67(5):754-60. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17608815].
Robb KA, Miles A, Wardle J. Demographic and psychosocial factors associated with perceived risk for colorectal cancer. Cancer Epidemiol Biomarkers Prev. 2004;13(3):366-72. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15006910].
Robinson RF, Batisky DL, Hayes JR, et al. Body mass index in primary and secondary pediatric hypertension. Pediatr Nephrol. 2004;19(12):1379-84. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15503182].
Rodriguez C, Plasencia A, Schroeder DG. Predictive factors of enrollment and adherence in a breast cancer screening program in Barcelona (Spain). Soc Sci Med. 1995;40(8):1155-60. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 7597469].
Rodriguez C, Calle EE, Tatham LM, et al. Family history of breast cancer as a predictor for fatal prostate cancer. Epidemiology. Sep. 1998;9(5):525-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9730031].
Roglic G, Colhoun HM, Stevens LK, et al. Parental history of hypertension and parental history of diabetes and microvascular complications in insulin-dependent diabetes mellitus: the EURODIAB IDDM Complications Study. Diabet Med. May. 1998;15(5):418-26. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9609365].
Rohrer J, Rohland B, Denison A, et al. Family history of mental illness and frequent mental distress in community clinic patients. J Eval Clin Pract. Jun. 2007;13(3):435-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17518811].
Roncaglioni MC, Avanzini F, Roccatagliata D, et al. How general pratitioners perceive and grade the cardiovascular risk of their patients. Eur J Cardiovasc Prev Rehabil. 2004;11(3):233-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15179106].
Ronco AL, De Stefani E, Boffetta P, et al. Food patterns and risk of breast cancer: A factor analysis study in Uruguay. Int J Cancer. 2006;119(7):1672-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16708380].
Ronmark E, Lundback B, Jonsson E, et al. Incidence of asthma in adults - Report from the obstructive lung disease in Northern Sweden study. Allergy. 1997;52(11):1071-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9404558].
Ronmark E, Lundback B, Jonsson E, et al. Asthma, type-1 allergy and related conditions in 7- and 8-year-old children in Northern Sweden: Prevalence rates and risk factor pattern. Respir Med. 1998;92(2):316-24. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9616532].
Rose PW, Watson E, Yudkin P, et al. Referral of patients with a family history of breast/ovarian cancer--GPs' knowledge and expectations. Fam Pract. Oct. 2001;18(5):487-90. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11604368].
Rose PW, Murphy M, Munafo M, et al. Improving the ascertainment of families at high risk of colorectal cancer: a prospective GP register study. Br J Gen Pract. Apr. 2004;54(501):267-71. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15113493].
Rosenbaum M, Nonas C, Horlick M, et al. beta-Cell function and insulin sensitivity in early adolescence: association with body fatness and family history of type 2 diabetes mellitus. J Clin Endocrinol Metab. Nov. 2004;89(11):5469-76. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15531499].
Roumier X, Azzouzi R, Valeri A, et al. Adherence to an annual PSA screening program over 3 years for brothers and sons of men with prostate cancer. Eur Urol. 2003;45(3):280-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Roux C, Fardellone P, Lespessailles E, et al. Prevalence of risk factors for referring post-menopausal women for bone densitometry. The INSTANT study. Joint, Bone, Spine. Dec. 2008;75(6):702-7. Excluded because no eligible outcomes presented. [pmid: 18617431].
Rowe MG, Fleming MF, Barry KL, et al. Correlates of depression in primary care. J Fam Pract. 1995;41(6):551-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 7500064].
Royak-Schaler R, Klabunde CN, Greene WF, et al. Communicating breast cancer risk: patient perceptions of provider discussions. Medscape Womens Health. 2002;7(2):2. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Rubin DT, LoSavio A, Yadron N, et al. Aminosalicylate Therapy in the Prevention of Dysplasia and Colorectal Cancer in Ulcerative Colitis. Clin Gastroenterol Hepatol. 2006;4(11):1346-50. Excluded because no eligible outcomes presented. [pmid: 17059900].
Rumboldt M, Rumboldt Z, Pesenti S. Premature parental heart attack is heralding elevated risk in their offspring. Coll Antropol. Jun. 2003;27(1):221-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12974150].
Ruo L, Cellini C, La Calle JP Jr, et al. Limitations of family cancer history assessment at initial surgical consultation. Dis Colon Rectum. Apr. 1999;44(1):98-103. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Russell MB, Fenger K, Olesen J. The family history of migraine. Direct versus indirect information. Cephalalgia. May. 1996;16(3):156-60. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8734766].
Ryabikov A, Malyutina S, Ryabikov M, et al. Intrafamilial correlations of carotid intima-media thickness and flow-mediated dilation in a Siberian population. Am J Hypertens. Mar. 2007;20(3):248-54. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17324734].
Saghafi H, Mahmoodi MJ, Fakhrzadeh H, et al. Cardiovascular risk factors in first-degree relatives of patients with premature coronary artery disease. Acta Cardiol. Dec. 2006;61(6):607-13. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17205917].
Sahakyan A, Armenian HK, Breitscheidel L, et al. Feeding practices of babies and the development of atopic dermatitis in children after 12 months of age in Armenia: Is there a signal?. Eur J Epidemiol. 2006;21(9):723-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17048079].
Saito T, Nanri S, Saito I, et al. A novel approach to assessing family history in the prevention of coronary heart disease. J Epidemiol. Jun. 1997;7(2):85-92. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9255029].
Saito T, Saito I, Nanri S, et al. A quantitative evaluation of the effects of sex and age on the positivity of family history of hypertension. J Epidemiol. Jun. 1998;8(2):99-105. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9673079].
Saito T, Furukawa T, Nanri S, et al. Potential errors resulting from sex and age difference in assessing family history of diabetes. Prev Med. Jan. 1999;28(1):33-9. Excluded because no eligible outcomes presented. [pmid: 9973586].
Saito T, Nanri S, Saito I, et al. Importance of sex and age factor in assessing family history of stroke. J Epidemiol. Sep. 2000;10(5):328-34. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11059516].
Saito T, Furukawa T, Nanri S, et al. Potential errors resulting from sex and age difference in assessing family history of coronary heart disease. J Epidemiol. Mar. 2004;14(2):51-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15162978].
Salem MB, Al Sadoon IO, Hassan MK. Prevalence of wheeze among preschool children in Basra governonate, southern Iraq. East Mediterr Health J. Jul. 2002;8(4–5):503-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15603031].
Salinas CA, Koopmeiners JS, Kwon EM, et al. Clinical utility of five genetic variants for predicting prostate cancer risk and mortality. Prostate. Mar. 1. 2009;69(4):363-72. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 19058137].
Salminen M, Vahlberg T, Kivela SL. Effects of family-oriented risk-based prevention on serum cholesterol and blood pressure values of children and adolescents. Scand J Prim Health Care. Mar. 2005;23(1):34-41. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16025872].
Sanders T, Campbell R, Sharp D, et al. Risk constructions among people who have a first-degree relative with cancer. Health Risk Soc. Mar. 2003;5(1):53-69. Excluded because not an eligible study design.
Sandhu MS, Luben R, Khaw KT. Self reported non-insulin dependent diabetes, family history, and risk of prevalent colorectal cancer: population based, cross sectional study. J Epidemiol Community Health. Nov. 2001;55(11):804-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11604436].
Santos-Ayarzagoitia M, Salinas-Martinez AM, Villarreal-Perez JZ. Gestational diabetes: Validity of ADA and WHO diagnostic criteria using NDDG as the reference test. Diabetes Res Clin Pract. 2006;74(3):322-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16730839].
Saraclar Y, Sekerel BE, Kalayci O, et al. Prevalence of asthma symptoms in school children in Ankara, Turkey. Respir Med. 1998;92(2):203-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9616513].
Saraiya M, Coughlin SS, Burke W, et al. The role of family history in personal prevention practices among US women physicians. Community Genet. 2001;4(2):102-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Satia JA, McRitchie S, Kupper LL, et al. Genetic testing for colon cancer among African-Americans in North Carolina. Prev Med. Jan. 2006;42(1):51-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16297974].
Sausenthaler S, Kompauer I, Borte M, et al. Margarine and butter consumption, eczema and allergic sensitization in children. The LISA birth cohort study. Pediatr Allergy Immunol. 2006;17(2):85-93. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16618357].
Sautter FJ, Cornwell J, Johnson JJ, et al. Family history study of posttraumatic stress disorder with secondary psychotic symptoms. Am J Psychiatry. Oct. 2002;159(10):1775-7. Excluded because no eligible outcomes presented. [pmid: 12359686].
Schambeck CM, Schwender S, Haubitz I, et al. Selective screening for the Factor V Leiden mutation: Is it advisable prior to the prescription of oral contraceptives?. Thromb Haemost. 1997;78(6):1480-3. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9423798].
Schattner A, Kasher I, Berrebi A. Causes and outcome of deep-vein thrombosis in otherwise-healthy patients under 50 years. QJM. 1997;90(4):283-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9307763].
Scheuner MT, Wang SJ, Raffel LJ, et al. Family history: a comprehensive genetic risk assessment method for the chronic conditions of adulthood. Am J Med Genet. Aug. 22. 1997;71(3):315-24. Excluded because no eligible outcomes presented. [pmid: 9268102].
Scheuner MT, Setodji CM, Pankow JS, et al. Relation of familial patterns of coronary heart disease, stroke, and diabetes to subclinical atherosclerosis: the multi-ethnic study of atherosclerosis. Genet Med. Dec. 2008;10(12):879-87. Excluded because no eligible outcomes presented. [pmid: 19092440].
Schmidt MI, Duncan BB, Bang H, et al. Identifying individuals at high risk for diabetes: The Atherosclerosis Risk in Communities study. Diabetes Care. 2005;28(8):2013-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16043747].
Scholte op Reimer WJM, Moons P, De Geest S, et al. Cardiovascular risk estimation by professionally active cardiovascular nurses: Results from the Basel 2005 Nurses Cohort. Eur J Cardiovasc Nurs. 2006;5(4):258-63. Excluded because no eligible outcomes presented. [pmid: 16908217].
Schranz AG, Savona-Ventura C. Long-term significance of gestational carbohydrate intolerance: A longitudinal study. Exp Clin Endocrinol Diabetes. 2002;110(5):219-22. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12148085].
Schroy PC III, Barrison AF, Ling BS, et al. Family history and colorectal cancer screening: a survey of physician knowledge and practice patterns. Am J Gastroenterol. Apr. 2002;97(4):1031-6. Excluded because family history not collected. [pmid: 12008667].
Schulz UG, Flossmann E, Rothwell PM. Heritability of ischemic stroke in relation to age, vascular risk factors, and subtypes of incident stroke in population-based studies. Stroke. Apr. 2004;35(4):819-24. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15001788].
Schumacher MC, Slattery ML, Lanier AP, et al. Prevalence and predictors of cancer screening among American Indian and Alaska native people: The EARTH study. Cancer Causes Control. 2008;19(7):725-37. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18307048].
Schuurman AG, Zeegers MP, Goldbohm RA, et al. A case-cohort study on prostate cancer risk in relation to family history of prostate cancer. Epidemiology. Mar. 1999;10(2):192-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10069259].
Schwartz AG, Yang P, Swanson GM. Familial risk of lung cancer among nonsmokers and their relatives. Am J Epidemiol. Sep. 15. 1996;144(6):554-62. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8797515].
Schwartz AG, Rothrock M, Yang P, et al. Increased cancer risk among relatives of nonsmoking lung cancer cases. Genet Epidemiol. 1999;17(1):1-15. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10323181].
Schwartz AG, Siegfried JM, Weiss L. Familial aggregation of breast cancer with early onset lung cancer. Genet Epidemiol. Nov. 1999;17(4):274-84. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10520210].
Schwartz MD, Rimer BK, Daly M, et al. A randomized trial of breast cancer risk counseling: The impact on self-reported mammography use. Am J Public Health. Jun. 1999;89(6):924-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10358689].
Schwartz MD, Valdimarsdottir HB, DeMarco TA, et al. Randomized trial of a decision aid for BRCA1/BRCA2 mutation carriers: Impact on measures of decision making and satisfaction. Health Psychol. Jan. 2009;28(1):11-9. Excluded because not an eligible population. [pmid: 19210013].
Sekine I, Abe N, Tsugane S, et al. Does smoking or family history influence the prognosis of patients with non-small cell lung cancer?. Oncol Rep. 1997;4(6):1221-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Sellers TA, Bazyk AE, Bostick RM, et al. Diet and risk of colon cancer in a large prospective study of older women: an analysis stratified on family history (Iowa, United States). Cancer Causes Control. Aug. 1998;9(4):357-67. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9794167].
Sellers TA, Walsh AJ, Grabrick DM, et al. Family history, ethnicity, and relative risk of breast cancer in a prospective cohort study of older women. Cancer Epidemiol Biomarkers Prev. May. 1999;8(5):421-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10350437].
Sellers TA, Davis J, Cerhan JR, et al. Interaction of waist/hip ratio and family history on the risk of hormone receptor-defined breast cancer in a prospective study of postmenopausal women. Am J Epidemiol. Feb. 1. 2002;155(3):225-33. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11821247].
Sellers TA, Grabrick DM, Vierkant RA, et al. Does folate intake decrease risk of postmenopausal breast cancer among women with a family history?. Cancer Causes Control. Mar. 2004;15(2):113-20. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15017123].
Seow A, Quah SR, Nyam D, et al. Food groups and the risk of colorectal carcinoma in an Asian population. Cancer. 2002;95(11):2390-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12436447].
Shah M, Zhu K, Palmer RC, et al. Breast, colorectal, and skin cancer screening practices and family history of cancer in U.S. women. J Womens Health (Larchmt). May. 2007;16(4):526-34. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17521256].
Shah M, Zhu K, Palmer RC, et al. Family history of cancer and utilization of prostate, colorectal and skin cancer screening tests in U.S. men. Prev Med. May. 2007;44(5):459-64. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17320159].
Shah S, Torner J, Mehta A. Prevalence of amblyogenic risk factors in siblings of patients with accommodative esotropia. J AAPOS. Oct. 2008;12(5):487-9. Excluded because no eligible outcomes presented. [pmid: 18534882].
Shaham J, Gurvich R, Goral A, et al. The risk of breast cancer in relation to health habits and occupational exposures. Am J Ind Med. 2006;49(12):1021-30. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17099904].
Sheinfeld GS, Albert SM. The meaning of risk to first degree relatives of women with breast cancer. Women Health. 2003;37(3):97-117. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12839310].
Sherman JJ, Cordova MJ, Wilson JF, et al. The effects of age, gender, and family history on blood pressure of normotensive college students. J Behav Med. Dec. 1996;19(6):563-75. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8970915].
Shirakawa T, Ozono R, Kasagi F, et al. Differential impact of family history on age-associated increase in the prevalence of hypertension and diabetes in male Japanese workers. Hypertens Res. Feb. 2006;29(2):81-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16755141].
Siegmund KD, Province MA, Higgins M, et al. Modeling disease incidence rates in families. Epidemiology. Sep. 1998;9(5):557-62. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9730037].
Sifri RD, Wender R, Paynter N. Cancer risk assessment from family history: gaps in primary care practice. J Fam Pract. Oct. 2002;51(10):856. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Silberberg JS, Wlodarczyk J, Fryer J, et al. Risk associated with various definitions of family history of coronary heart disease. The Newcastle Family History Study II. Am J Epidemiol. Jun. 15. 1998;147(12):1133-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9645791].
Silvera SA, Miller AB, Rohan TE. Oral contraceptive use and risk of breast cancer among women with a family history of breast cancer: a prospective cohort study. Cancer Causes Control. Nov. 2005;16(9):1059-63. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16184471].
Simon MS, Korczak JF, Yee CL, et al. Racial differences in the familial aggregation of breast cancer and other female cancers. Breast Cancer Res Treat. Feb. 2005;89(3):227-35. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15754120].
Simon MS, Korczak JF, Yee CL, et al. Breast cancer risk estimates for relatives of white and African American women with breast cancer in the Women's Contraceptive and Reproductive Experiences Study. J Clin Oncol. Jun. 1. 2006;24(16):2498-504. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16735703].
Singh T, Mullick SS, Calton R, et al. Quantification of coronary risk score. Indian J Pediatr. Jan. 2002;69(1):27-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11876116].
Sipetic S, Vlajinac H, Kocev N, et al. Family history and risk of type 1 diabetes mellitus. Acta Diabetol. Sep. 2002;39(3):111-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12357294].
Sipetic SB, Vlajinac HD, Kocev NI, et al. The Belgrade childhood diabetes study: A multivariate analysis of risk determinants for diabetes. Eur J Public Health. 2005;15(2):117-22. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15941756].
Siritho S, Thrift AG, McNeil JJ, et al. Risk of ischemic stroke among users of the oral contraceptive pill: The Melbourne Risk Factor Study (MERFS) Group. Stroke. 2003;34(7):1575-80. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12805499].
Skinner HG, Schwartz GG. Serum calcium and incident and fatal prostate cancer in the national health and nutrition examination survey. Cancer Epidemiol Biomarkers Prev. 2008;17(9):2302-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18768497].
Slanger T, Mutschelknauss E, Kropp S, et al. Test-retest reliability of self-reported reproductive and lifestyle data in the context of a German case-control study on breast cancer and postmenopausal hormone therapy. Ann Epidemiol. Dec. 2007;17(12):993-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17855123].
Slattery ML, Mineau GP, Kerber RA. Reproductive factors and colon cancer: the influences of age, tumor site, and family history on risk (Utah, United States). Cancer Causes Control. Jul. 1995;6(4):332-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 7548720].
Slattery ML, Potter JD, Duncan DM, et al. Dietary fats and colon cancer: assessment of risk associated with specific fatty acids. Int J Cancer. Nov. 27. 1997;73(5):670-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9398044].
Slattery ML, Potter JD, Ma KN, et al. Western diet, family history of colorectal cancer, NAT2, GSTM-1 and risk of colon cancer. Cancer Causes Control. Jan. 2000;11(1):1-8. Excluded because not an eligible population. [pmid: 10680724].
Slattery ML, Levin TR, Ma K, et al. Family history and colorectal cancer: predictors of risk. Cancer Causes Control. Nov. 2003;14(9):879-87. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14682445].
Slattery ML, Kinney AY, Levin TR. Factors associated with colorectal cancer screening in a population-based study: The impact of gender, health care source, and time. Prev Med. 2004;38(3):276-83. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14766109].
Slattery ML, Sweeney C, Murtaugh M, et al. Associations between apoE genotype and colon and rectal cancer. Carcinogenesis. 2005;26(8):1422-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15817610].
Smith AW, Dougall AL, Posluszny DM, et al. Psychological distress and quality of life associated with genetic testing for breast cancer risk. Psychooncology. 2008;17(8):767-73. Excluded because family history not collected. [pmid: 17992698].
Smyth DJ, Plagnol V, Walker NM, et al. Shared and distinct genetic variants in type 1 diabetes and celiac disease. N Engl J Med. Dec. 25. 2008;359(26):2767-77. Excluded because family history not collected. [pmid: 19073967].
Soliman AS, Bondy ML, Levin B, et al. Familial aggregation of colorectal cancer in Egypt. Int J Cancer. Sep. 11. 1998;77(6):811-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9714045].
Solomon CG, Willett WC, Carey VJ, et al. A prospective study of pregravid determinants of gestational diabetes mellitus. JAMA. 1997;278(13):1078-83. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9315766].
Somnath CP, Janardhan Reddy YC, Jain S. Is there a familial overlap between schizophrenia and bipolar disorder?. J Affect Disord. 2002;72(3):243-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12450641].
Spencer BA, Babey SH, Etzioni DA, et al. A population-based survey of prostate-specific antigen testing among California men at higher risk for prostate carcinoma. Cancer. Feb. 15. 2006;106(4):765-74. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16419068].
Spencer L. Results of a heart disease risk-factor screening among traditional college students. J Am Coll Health. May. 2002;50(6):291-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12701654].
St Sauver JL, Hagen PT, Cha SS, et al. Agreement between patient reports of cardiovascular disease and patient medical records. Mayo Clin Proc. Feb. 2005;80(2):203-10. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15704775].
Stabile A, Sopo SM, Guerrini B, et al. In vitro production of interleukin-4 and interferon-gamma after PHA and PMA stimulation, and mononuclear cell proliferative response to betalactoglobulin and ovalbumin in neonates with different family history of atopy. A follow-up of five years. Pediatr Asthma Allergy Immunol. 1998;12(4):259-70. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Staples MP, Giles GG, English DR, et al. Risk of prostate cancer associated with a family history in an era of rapid increase in prostate cancer diagnosis (Australia). Cancer Causes Control. Mar. 2003;14(2):161-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12749721].
Stark JR, Bertone-Johnson ER, Costanza ME, et al. Factors associated with colorectal cancer risk perception: the role of polyps and family history. Health Educ Res. Oct. 2006;21(5):740-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16801376].
Steck AK, Barriga KJ, Emery LM, et al. Secondary attack rate of type 1 diabetes in Colorado families. Diabetes Care. Feb. 2005;28(2):296-300. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15677782].
Stefansson T, Moller PH, Sigurdsson F, et al. Familial risk of colon and rectal cancer in Iceland: evidence for different etiologic factors?. Int J Cancer. Jul. 15. 2006;119(2):304-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16477631].
Steinberg KK, Pernarelli JM, Marcus M, et al. Increased risk for familial ovarian cancer among Jewish women: a population-based case-control study. Genet Epidemiol. 1998;15(1):51-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9523210].
Stencel-Gabriel K, Obuchowicz A, Paul M, et al. Serum IgE levels during first 18 months of life in newborns from Upper Silesia. Int Rev Allergol Clin Immunol. 2006;12(2):56-60. Excluded because no eligible outcomes presented.
Stensland-Bugge E, Bonaa KH, Joakimsen O. Age and sex differences in the relationship between inherited and lifestyle risk factors and subclinical carotid atherosclerosis: the Tromso study. Atherosclerosis. Feb. 1. 2001;154(2):437-48. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11166777].
Stephens JH, Moore JW. Can targeted intervention in CRC patients' relatives influence screening behaviour? A pilot study. Colorectal Dis. Feb. 2008;10(2):179-86. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17459064].
Stick SM, Burton PR, Gurrin L, et al. Effects of maternal smoking during pregnancy and a family history of asthma on respiratory function in newborn infants. Lancet. Oct. 19. 1996;348(9034):1060-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8874457].
Stone SN, Hoffman RM, Tollestrup K, et al. Family history, Hispanic ethnicity, and prostate cancer risk. Ethn Dis. 2003;13(2):233-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12785421].
Stoney CM, Hughes JW. Lipid reactivity among men with a parental history of myocardial infarction. Psychophysiology. Jul. 1999;36(4):484-90. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10432798].
Strauss ME, Ogrocki PK. Confirmation of an association between family history of affective disorder and the depressive syndrome in Alzheimer's disease. Am J Psychiatry. Oct. 1996;153(10):1340-2. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8831446].
Strom SS, Yamamura Y, Flores-Sandoval FN, et al. Prostate cancer in Mexican-Americans: Identification of risk factors. Prostate. 2008;68(5):563-70. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18247399].
Strum WB. Impact of a family history of colorectal cancer on age at diagnosis, anatomic location, and clinical characteristics of colorectal cancer. Int J Gastrointest Cancer. 2005;35(2):121-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15879626].
Strum WB. Impact of a family history of colorectal cancer on the prevalence of advanced adenomas of the rectosigmoid colon at flexible sigmoidoscopy in 3147 asymptomatic patients. Dig Dis Sci. 2006;51(11):2048-52. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17072763].
Sugano K, Nakamura S, Ando J, et al. Cross-sectional analysis of germline BRCA1 and BRCA2 mutations in Japanese patients suspected to have hereditary breast/ovarian cancer. Cancer Sci. Oct. 2008;99(10):1967-76. Excluded because not an eligible population. [pmid: 19016756].
Sullivan PF, Wells JE, Joyce PR, et al. Family history of depression in clinic and community samples. J Affect Disord. Oct. 1996;40(3):159-68. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8897115].
Summerton N, Garrood PV. The family history in family practice: a questionnaire study. Fam Pract. Aug. 1997;14(4):285-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9283847].
Sundell J, Laine H, Raitakari OT, et al. Positive family history of coronary artery disease is associated with reduced myocardial vasoreactivity in healthy men. Int J Cardiol. Oct. 10. 2006;112(3):289-94. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16298443].
Sunsaneevithayakul P, Sutanthavibul A, Kanokpongsakdi S, et al. Risk factor-based selective screening program for gestational diabetes mellitus in Siriraj Hospital: Result from clinical practice guideline. J Med Assoc Thai. 2003;86(8):708-14. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12948268].
Sutherland HJ, Lacroix J, Knight J, et al. The Cooperative Familial Registry for Breast Cancer Studies: design and first year recruitment rates in Ontario. J Clin Epidemiol. Jan. 2001;54(1):93-8. Excluded because no eligible outcomes presented. [pmid: 11165472].
Suzuki T, Matsuo K, Wakai K, et al. Effect of familial history and smoking on common cancer risks in Japan. Cancer. 2007;109(10):2116-23. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17410537].
Svanes C, Jarvis D, Chinn S, et al. Childhood environment and adult atopy: results from the European Community Respiratory Health Survey. J Allergy Clin Immunol. Mar. 1999;103(3:Pt 1):415-20. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10069874].
Sveger T, Flodmark C-E, Nordborg K, et al. Hereditary dyslipidaemias and combined risk factors in children with a family history of premature coronary artery disease. Arch Dis Child. 2000;82(4):292-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10735834].
Svensson J, Carstensen B, Mortensen HB, et al. Early childhood risk factors associated with type 1 diabetes - Is gender important?. Eur J Epidemiol. 2005;20(5):429-34. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16080591].
Sweeney C, Blair CK, Anderson KE, et al. Risk factors for breast cancer in elderly women. Am J Epidemiol. Nov. 1. 2004;160(9):868-75. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15496539].
Sweet KM, Bradley TL, Westman JA. Identification and referral of families at high risk for cancer susceptibility. J Clin Oncol. Jan. 15. 2002;20(2):528-37. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11786583].
Swerdlow AJ, De Stavola BL, Floderus B, et al. Risk factors for breast cancer at young ages in twins: an international population-based study. J Natl Cancer Inst. Aug. 21. 2002;94(16):1238-46. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12189227].
Szczech R, Bieniaszewski L, Narkiewicz K, et al. Family history of hypertension: A novel and potent risk factor for premature coronary artery disease. Kardiol Pol. 2002;56(1):68-71. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Szelei-Stevens KA, Kuske RR, Yantsos VA, et al. The influence of young age and positive family history of breast cancer on the prognosis of ductal carcinoma in situ treated by excision with or without radiation therapy or by mastectomy. Int J Radiat Oncol Biol Phys. Nov. 1. 2000;48(4):943-9. Excluded because no eligible outcomes presented. [pmid: 11072149].
Taira K, Bujo H, Kobayashi J, et al. Positive family history for coronary heart disease and 'midband lipoproteins' are potential risk factors of carotid atherosclerosis in familial hypercholesterolemia. Atherosclerosis. Feb. 2002;160(2):391-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11849663].
Tam WH, Yang XL, Chan JCN, et al. Progression to impaired glucose regulation, diabetes and metabolic syndrome in Chinese women with a past history of gestational diabetes. Diabetes Metab Res Rev. 2007;23(6):485-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17410525].
Tammemagi CM, Freedman MT, Church TR, et al. Factors associated with human small aggressive non-small cell lung cancer. Cancer Epidemiol Biomarkers Prev. 2007;16(10):2082-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17932357].
Tanaka K, Miyake Y, Sasaki S, et al. Maternal smoking and environmental tobacco smoke exposure and the risk of allergic diseases in Japanese infants: The Osaka maternal and child health study. J Asthma. 2008;45(9):833-8. Excluded because no eligible outcomes presented. [pmid: 18972305].
Taraboanta C, Wu E, Lear S, et al. Subclinical atherosclerosis in subjects with family history of premature coronary artery disease. Am Heart J. Jun. 2008;155(6):1020-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18513514].
Tavani A, Braga C, La Vecchia C, et al. Attributable risks for breast cancer in Italy: education, family history and reproductive and hormonal factors. Int J Cancer. Jan. 17. 1997;70(2):159-63. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9009154].
Tavani A, Ricci E, La Vecchia C, et al. Influence of menstrual and reproductive factors on ovarian cancer risk in women with and without family history of breast or ovarian cancer. Int J Epidemiol. Oct. 2000;29(5):799-802. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11034959].
Tavani A, Bosetti C, Dal Maso L, et al. Influence of selected hormonal and lifestyle factors on familial propensity to ovarian cancer. Gynecol Oncol. Mar. 2004;92(3):922-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14984961].
Tavani A, Bertuzzi M, Gallus S, et al. Risk factors for non-fatal acute myocardial infarction in Italian women. Prev Med. 2004;39(1):128-34. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15207993].
Tavani A, Augustin L, Bosetti C, et al. Influence of selected lifestyle factors on risk of acute myocardial infarction in subjects with familial predisposition for the disease. Prev Med. Apr. 2004;38(4):468-72. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15020180].
Taylor AJ, Bindeman J, Bhattarai S, et al. Subclinical calcified atherosclerosis in men and its association with a family history of premature coronary heart disease in first- and second-degree relatives. Prev Cardiol. 2004;7(4):163-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15539962].
Taylor R, Boyages J. Absolute risk of breast cancer for Australian women with a family history. Aust N Z J Surg. Oct. 2000;70(10):725-31. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11021486].
Terdiman JP, Levin TR, Allen BA, et al. Hereditary nonpolyposis colorectal cancer in young colorectal cancer patients: High-risk clinic versus population-based registry. Gastroenterology. 2002;122(4):940-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11910346].
Thalib L, Wedren S, Granath F, et al. Breast cancer prognosis in relation to family history of breast and ovarian cancer. Br J Cancer. Apr. 5. 2004;90(7):1378-81. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15054458].
Thompson IM, Ankerst DP, Chi C, et al. Prediction of prostate cancer for patients receiving finasteride: Results from the prostate cancer prevention trial. J Clin Oncol. 2007;25(21):3076-81. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17634486].
Thomsen SF, Ulrik CS, Kyvik KO, et al. Importance of genetic factors in the etiology of atopic dermatitis: a twin study. Allergy Asthma Proc. Sep. 2007;28(5):535-9. Excluded because family history not collected. [pmid: 18034971].
Thorand B, Liese AD, Metzger MH, et al. Can inaccuracy of reported parental history of diabetes explain the maternal transmission hypothesis for diabetes?. Int J Epidemiol. Oct. 2001;30(5):1084-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11689527].
Tiller K, Meiser B, Gould L, et al. Knowledge of risk management strategies, and information and risk management preferences of women at increased risk for ovarian cancer. Psychooncology. Apr. 2005;14(4):249-61. Excluded because not an eligible population. [pmid: 15386771].
Timko C, Cronkite RC, Berg EA, et al. Children of parents with unipolar depression: A comparison of stably remitted, partially remitted, and nonremitted parents and nondepressed controls. Child Psychiatry Hum Dev. 2002;32(3):165-85. Excluded because family history not collected. [pmid: 11893169].
Timonen M, Jokelainen J, Herva A, et al. Presence of atopy in first-degree relatives as a predictor of a female proband's depression: Results from the Northern Finland 1966 Birth Cohort. J Allergy Clin Immunol. 2003;111(6):1249-54. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12789225].
Tomac N, Demirel F, Acun C, et al. Prevalence and risk factors for childhood asthma in Zonguldak, Turkey. Allergy Asthma Proc. Sep. 2005;26(5):397-402. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16450575].
Tonstad S, Refsum H, Sivertsen M, et al. Relation of total homocysteine and lipid levels in children to premature cardiovascular death in male relatives. Pediatr Res. Jul. 1996;40(1):47-52. Excluded because no eligible outcomes presented. [pmid: 8798245].
Toren K, Hermansson B-A. Incidence rate of adult-onset asthma in relation to age, sex, atopy and smoking: A Swedish population-based study of 15 813 adults. Int J Tuberc Lung Dis. 1999;3(3):192-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10094318].
Tozzi F, Prokopenko I, Perry JD, et al. Family history of depression is associated with younger age of onset in patients with recurrent depression. Psychol Med. 2008;38(5):641-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18272011].
Tracy KA, Quillin JM, Wilson DB, et al. The impact of family history of breast cancer and cancer death on women's mammography practices and beliefs. Genet Med. Aug. 2008;10(8):621-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18641520].
Tremeau F, Staner L, Duval F, et al. Suicide attempts and family history of suicide in three psychiatric populations. Suicide Life Threat Behav. 2005;35(6):702-13. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16552986].
Trentham-Dietz A, Newcomb PA, Nichols HB, et al. Breast cancer risk factors and second primary malignancies among women with breast cancer. Breast Cancer Res Treat. Oct. 2007;105(2):195-207. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17186360].
Tripathy D, Lindholm E, Isomaa B, et al. Familiality of metabolic abnormalities is dependent on age at onset and phenotype of the type 2 diabetic proband. Am J Physiol Endocrinol Metab. Dec. 2003;285(6):E1297-E1303. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12954593].
Tsolaki M, Fountoulakis K, Chantzi E, et al. Risk factors for clinically diagnosed Alzheimer's disease: A case-control study of a Greek population. Int Psychogeriatr. 1997;9(3):327-41. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9513031].
Tung KH, Goodman MT, Wu AH, et al. Aggregation of ovarian cancer with breast, ovarian, colorectal, and prostate cancer in first-degree relatives. Am J Epidemiol. Apr. 15. 2004;159(8):750-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15051584].
Ture M, Kurt I, Kurum T. Analysis of intervariable relationships between major risk factors in the development of coronary artery disease: A classification tree approach. Anadolu Kardiyoloji Dergisi. 2007;7(2):140-5. Excluded because no eligible outcomes presented. [pmid: 17513208].
Tyagi A, Morris J. Using decision analytic methods to assess the utility of family history tools. Am J Prev Med. Feb. 2003;24(2):199-207. Excluded because not an eligible population. [pmid: 12568827].
Tyndel S, Clements A, Bankhead C, et al. Mammographic screening for young women with a family history of breast cancer: Knowledge and views of those at risk. Br J Cancer. 2008;99(7):1007-12. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18827822].
Tytherleigh MG, Ng VV, Mathew LO, et al. Colonoscopy for screening and follow up of patients with a family history of colorectal cancer. Colorectal Dis. Jun. 2008;10(5):506-11. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18318755].
Tytherleigh MG, Ng VV, Mathew LO, et al. Colonoscopy for screening and follow up of patients with a family history of colorectal cancer. Colorectal Dis. 2008;10(5):506-11. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18318755].
Uchigata Y, Otani T, Takaike H, et al. Time-course changes in clinical features of early-onset Japanese type 1 and type 2 diabetes: TWMU hospital-based study. Diabetes Res Clin Pract. Oct. 2008;82(1):80-6. Excluded because no eligible outcomes presented. [pmid: 18707790].
Ueda K, Tsukuma H, Tanaka H, et al. Estimation of individualized probabilities of developing breast cancer for Japanese women. Breast Cancer. 2003;10(1):54-62. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12525764].
Urashima M, Wada T, Fukumoto T, et al. Prevalence of metabolic syndrome in a 22,892 Japanese population and its association with life style. JMAJ. 2005;48(9):441-50. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Uzzo RG, Brown JG, Horwitz EM, et al. Prevalence and patterns of self-initiated nutritional supplementation in men at high risk of prostate cancer. BJU Int. May. 2004;93(7):955-60. Excluded because family history not collected. [pmid: 15142142].
Valdez R, Yoon PW, Liu T, et al. Family history and prevalence of diabetes in the U.S. population: the 6-year results from the National Health and Nutrition Examination Survey (1999–2004). Diabetes Care. Oct. 2007;30(10):2517-22. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17634276].
Valentine RJ, Verstraete R, Clagett GP, et al. Premature cardiovascular disease is common in relatives of patients with premature peripheral atherosclerosis. Arch Intern Med. May. 8. 2000;160(9):1343-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10809039].
van der Net JB, Janssens AC, Defesche JC, et al. Usefulness of genetic polymorphisms and conventional risk factors to predict coronary heart disease in patients with familial hypercholesterolemia. Am J Cardiol. Feb. 1. 2009;103(3):375-80. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 19166692].
Van Der Sande MA, Walraven GE, Milligan PJ, et al. Family history: an opportunity for early interventions and improved control of hypertension, obesity and diabetes. Bull World Health Organ. 2001;79(4):321-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11357211].
van Dijk DA, Oostindier MJ, Kloosterman-Boele WM, et al. Family history is neglected in the work-up of patients with colorectal cancer: a quality assessment using cancer registry data. Fam Cancer. 2007;6(1):131-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17237905].
van Dooren S, Seynaeve C, Rijnsburger AJ, et al. The impact of having relatives affected with breast cancer on psychological distress in women at increased risk for hereditary breast cancer. Breast Cancer Res Treat. Jan. 2005;89(1):75-80. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15666200].
van Ojen R, Hooijer C, Bezemer D, et al. Late-life depressive disorder in the community: II. The relationship between psychiatric history, MMSE and family history. Br J Psychiatry. Mar. 1995;166(3):316-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 7788122].
Van dAI, Van Golde RJ, Tuerlings JH, et al. Underestimation of subfertility among relatives when using a family history: taboo bias. J Androl. Mar. 2003;24(2):285-8. Excluded because no eligible outcomes presented. [pmid: 12634317].
Vasen HFA, Taal BG, Nagengast FM, et al. Hereditary nonpolyposis colorectal cancer: Results of long-term surveillance in 50 families. Eur J Cancer. 1995;31(7–8):1145-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Verkooijen HM, Fioretta G, Chappuis PO, et al. Set-up of a population-based familial breast cancer registry in Geneva, Switzerland: validation of first results. Ann Oncol. Feb. 2004;15(2):350-3. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14760133].
Verkooijen HM, Fioretta G, Rapiti E, et al. Family history of breast or ovarian cancer modifies the risk of secondary leukemia after breast cancer: results from a population-based study. Int J Cancer. Mar. 1. 2008;122(5):1114-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17973260].
Vestbo E, Damsgaard EM, Froland A, et al. Clinical features in persons with a family history of diabetes compared to controls (The Second Generation Fredericia Study). J Intern Med. Dec. 1996;240(6):381-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9010385].
Viana DV, Goes JR, Coy CS, et al. Family history of cancer in Brazil: is it being used?. Fam Cancer. 2008;7(3):229-32. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18193339].
Vicencio JCA, Gonzalez-Andaya AM. Sensitization to food and aeroallergens in children with atopic dermatitis seen at the University of Santo Tomas Hospital Allergy Clinic. Santo Tomas Journal of Medicine. 2005;52(3):92-100. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Vikram NK, Tandon N, Misra A, et al. Correlates of Type 2 diabetes mellitus in children, adolescents and young adults in north India: a multisite collaborative case-control study. Diabet Med. Mar. 2006;23(3):293-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16492213].
Viladiu P, Izquierdo A, de Sanjose S, et al. A breast cancer case-control study in Girona, Spain. Endocrine, familial and lifestyle factors. Eur J Cancer Prev. 1996;5(5):329-35. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8972251].
Villani AC, Lemire M, Fortin G, et al. Common variants in the NLRP3 region contribute to Crohn's disease susceptibility. Nat Genet. Jan. 2009;41(1):71-6. Excluded because not an eligible population. [pmid: 19098911].
Villarreal AB, Sanin Aguirre LH, Tellez Rojo MM, et al. Risk factors for asthma in school children from Ciudad Juarez, Chihuahua. J Asthma. 2003;40(4):413-23. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12870837].
Vitullo F, Marchioli R, Di Mascio R, et al. Family history and socioeconomic factors as predictors of myocardial infarction, unstable angina and stroke in an Italian population. PROGETTO 3A Investigators. Eur J Epidemiol. Apr. 1996;12(2):177-85. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8817197].
von Eyben FE, Mouritsen E, Holm J, et al. Smoking, low density lipoprotein cholesterol, fibrinogen and myocardial infarction before 41 years of age: A Danish case-control study. J Cardiovasc Risk. 2002;9(3):171-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12202840].
Wadonda-Kabondo N, Sterne JA, Golding J, et al. Association of parental eczema, hayfever, and asthma with atopic dermatitis in infancy: birth cohort study. Arch Dis Child. Oct. 2004;89(10):917-21. Excluded because no eligible outcomes presented. [pmid: 15383434].
Wakefield CE, Meiser B, Homewood J, et al. Randomized trial of a decision aid for individuals considering genetic testing for hereditary nonpolyposis colorectal cancer risk. Cancer. Sep. 2008;113(5):956-65. Excluded because no eligible outcomes presented. [pmid: 18618513].
Wakefield CE, Meiser B, Homewood J, et al. A randomized controlled trial of a decision aid for women considering genetic testing for breast and ovarian cancer risk. Breast Cancer Res Treat. Jan. 2008;107(2):289-301. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17333332].
Wakefield CE, Meiser B, Homewood J, et al. A randomized trial of a breast/ovarian cancer genetic testing decision aid used as a communication aid during genetic counseling. Psychooncology. Aug. 2008;17(8):844-54. Excluded because family history not collected. [pmid: 18613319].
Waldhoer T, Haidinger G, Feenstra O, et al. The influence of genetic predisposition on the prevalence of atopic diseases in Carinthian school children. Acta Med Austriaca. 2000;27(5):141-4. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11261263].
Waldhor T, Schober E, Rami B, et al. The prevalence of IDDM in the first degree relatives of children newly diagnosed with IDDM in Austria - A population-based study. Exp Clin Endocrinol Diabetes. 1999;107(5):323-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10482046].
Walker GR, Schlesselman JJ, Ness RB. Family history of cancer, oral contraceptive use, and ovarian cancer risk. Am J Obstet Gynecol. Jan. 2002;186(1):8-14. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11810077].
Wallace E, Hinds A, Campbell H, et al. A cross-sectional survey to estimate the prevalence of family history of colorectal, breast and ovarian cancer in a Scottish general practice population. Br J Cancer. Oct. 18. 2004;91(8):1575-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15381929].
Walsh PC, Partin AW. Family history facilitates the early diagnosis of prostate carcinoma. Cancer. Nov. 1. 1997;80(9):1871-4. Excluded because not an eligible study design. [pmid: 9351562].
Walter FM, Emery J. 'Coming down the line'-- patients' understanding of their family history of common chronic disease. Ann Fam Med. Sep. 2005;3(5):405-14. Excluded because not an eligible study design. [pmid: 16189056].
Walter FM, Emery J. Perceptions of family history across common diseases: a qualitative study in primary care. Fam Pract. Aug. 2006;23(4):472-80. Excluded because not an eligible study design. [pmid: 16608871].
Wang I-J, Guo YL, Hwang K-C, et al. Genetic and environmental predictors for pediatric atopic dermatitis. Acta Paediatrica Taiwanica. 2006;47(5):238-42. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17352311].
Wang NY, Young JH, Meoni LA, et al. Blood pressure change and risk of hypertension associated with parental hypertension: the Johns Hopkins Precursors Study. Arch Intern Med. Mar. 24. 2008;168(6):643-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18362257].
Wang TN, Chao YY, Wang TH, et al. Familial risk of asthma among adolescents and their relatives in Taiwan. J Asthma. Sep. 2001;38(6):485-94. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11642415].
Warner E, Goel V, Ondrusek N, et al. Pilot study of an information aid for women with a family history of breast cancer. Health Expect. 1999;2(2):118-28. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11281885].
Wattacheril J, Kramer JR, Richardson P, et al. Lagtimes in diagnosis and treatment of colorectal cancer: Determinants and association with cancer stage and survival. Aliment Pharmacol Ther. 2008;28(9):1166-74. Excluded because no eligible outcomes presented. [pmid: 18691351].
Webb PM, Byrne C, Schnitt SJ, et al. Family history of breast cancer, age and benign breast disease. Int J Cancer. Jul. 20. 2002;100(3):375-8. Excluded because no eligible outcomes presented. [pmid: 12115556].
Weeks SK, O'Connor PC. The FAMTOOL family health assessment tool. Rehabil Nurs. Jul. 1997;22(4):188-91. Excluded because family history not collected. [pmid: 9275809].
Wei JN, Sung FC, Lin CC, et al. National Surveillance for Type 2 Diabetes Mellitus in Taiwanese Children. JAMA. 2003;290(10):1345-50. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12966126].
Weinrich S, Royal C, Pettaway CA, et al. Interest in genetic prostate cancer susceptibility testing among african American men. Cancer Nurs. Feb. 2002;25(1):28-34. Excluded because no eligible outcomes presented. [pmid: 11838717].
Weinrich SP, Faison-Smith L, Hudson-Priest J, et al. Stability of self-reported family history of prostate cancer among African American men. J Nurs Meas. 2002;10(1):39-46. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12048968].
Weires MB, Tausch B, Haug PJ, et al. Familiality of diabetes mellitus. Exp Clin Endocrinol Diabetes. Nov. 2007;115(10):634-40. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18058597].
Weiss HA, Brinton LA, Brogan D, et al. Epidemiology of in situ and invasive breast cancer in women aged under 45. Br J Cancer. May. 1996;73(10):1298-305. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8630296].
West DS, Greene PG, Kratt PP, et al. The impact of a family history of breast cancer on screening practices and attitudes in low-income, rural, African American women. J Womens Health (Larchmt). Oct. 2003;12(8):779-87. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14588128].
Whitaker JA, Davis KL, Lauer C. Is there a need for screening for type 2 diabetes in seventh graders?. J Am Acad Nurse Pract. Nov. 2004;16(11):496-501. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15617363].
White DB, Bonham VL, Jenkins J, et al. Too many referrals of low-risk women for BRCA1/2 genetic services by family physicians. Cancer Epidemiol Biomarkers Prev. Nov. 2008;17(11):2980-6. Excluded because family history not collected. [pmid: 18990739].
White HL, Roberts DH. Cholesterol management in general practice. Curr Med Res Opin. 1997;14(1):53-62. Excluded because family history not collected. [pmid: 9524794].
Whittemore AS, Wu AH, Kolonel LN, et al. Family history and prostate cancer risk in black, white, and Asian men in the United States and Canada. Am J Epidemiol. Apr. 15. 1995;141(8):732-40. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 7535977].
Wickens K, Crane J, Kemp T, et al. A case-control study of risk factors for asthma in New Zealand children. Aust N Z J Public Health. 2001;25(1):44-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11297301].
Wickramaratne PJ, Greenwald S, Weissman MM. Psychiatric disorders in the relatives of probands with prepubertal-onset or adolescent-onset major depression. J Am Acad Child Adolesc Psychiatry. Nov. 2000;39(11):1396-405. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11068895].
Wiegman A, Rodenburg J, de Jongh S, et al. Family history and cardiovascular risk in familial hypercholesterolemia: data in more than 1000 children. Circulation. Mar. 25. 2003;107(11):1473-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12654602].
Wilhelmsen L, Lappas G, Rosengren A. Risk of coronary events by baseline factors during 28 years follow-up and three periods in a random population sample of men. J Intern Med. 2004;256(4):298-307. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 15367172].
Willemsen G, van Beijsterveldt TC, van Baal CG, et al. Heritability of self-reported asthma and allergy: a study in adult Dutch twins, siblings and parents. Twin Res Human Genet. Apr. 2008;11(2):132-42. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18361713].
Williams KP, Sheppard VB, Todem D, et al. Family matters in mammography screening among African-American women age [greater-than or equal to]40. J Natl Med Assoc. 2008;100(5):508-15. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18507203].
Williams MA, Qiu C, Dempsey JC, et al. Familial Aggregation of Type 2 Diabetes and Chronic Hypertension in Women with Gestational Diabetes Mellitus. J Reprod Med. 2003;48(12):955-62. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14738023].
Williams RR, Hunt SC, Heiss G, et al. Usefulness of cardiovascular family history data for population-based preventive medicine and medical research (the Health Family Tree Study and the NHLBI Family Heart Study). Am J Cardiol. Jan. 15. 2001;87(2):129-35. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11152826].
Williams T, Clarke V, Borland R. Breast cancer and family history: evaluation of a community resource. Health Promot J Aust. Dec. 2000;10(3):224-9. Excluded because no eligible outcomes presented.
Williamson DE, Ryan ND, Birmaher B, et al. A case-control family history study of depression in adolescents. J Am Acad Child Adolesc Psychiatry. Dec. 1995;34(12):1596-607. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8543531].
Winawer SJ, Zauber AG, Gerdes H, et al. Risk of colorectal cancer in the families of patients with adenomatous polyps. N Engl J Med. 1996;334(2):82-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8531963].
Wohlfahrt J, Olsen JH, Melbye M. Breast cancer risk after childbirth in young women with family history (Denmark). Cancer Causes Control. 2002;13(2):169-74. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11936823].
Wolf AMD, Nasser JF, Wolf AM, et al. The impact of informed consent on patient interest in prostate-specific antigen screening. Arch Intern Med. 1996;156(12):1333-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8651843].
Wolf AMD, Philbrick JT, Schorling JB. Predictors of interest in prostate-specific antigen screening and the impact of informed consent: What should we tell our patients?. Am J Med. 1997;103(4):308-14. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9382123].
Wong TY, Mohamed Q, Klein R, et al. Do retinopathy signs in non-diabetic individuals predict the subsequent risk of diabetes?. Br J Ophthalmol. 2006;90(3):301-3. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16488949].
Wood ME, Stockdale A, Flynn BS. Interviews with primary care physicians regarding taking and interpreting the cancer family history. Fam Pract. Oct. 2008;25(5):334-40. Excluded because not an eligible study design. [pmid: 18765407].
Woodward M, Brindle P, Tunstall-Pedoe H, et al. Adding social deprivation and family history to cardiovascular risk assessment: the ASSIGN score from the Scottish Heart Health Extended Cohort (SHHEC). Heart. Feb. 2007;93(2):172-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17090561].
Wrensch M, Chew T, Farren G, et al. Risk factors for breast cancer in a population with high incidence rates. Breast Cancer Res. 2003;5(4):R88-102. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12817999].
Wright CE, O'Donnell K, Brydon L, et al. Family history of cardiovascular disease is associated with cardiovascular responses to stress in healthy young men and women. Int J Psychophysiol. Mar. 2007;63(3):275-82. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17234292].
Wu AH, Fontham ET, Reynolds P, et al. Family history of cancer and risk of lung cancer among lifetime nonsmoking women in the United States. Am J Epidemiol. Mar. 15. 1996;143(6):535-42. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 8610670].
Wu PF, Lee CH, Wang MJ, et al. Cancer aggregation and complex segregation analysis of families with female non-smoking lung cancer probands in Taiwan. Eur J Cancer. Jan. 2004;40(2):260-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14728941].
Wyshak G. Behavior, heredity, and diabetes in college alumnae. J Wom Health Gend Base Med. 2002;11(6):549-54. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Yang P-S, Yang T-L, Liu C-L, et al. A case-control study of breast cancer in Taiwan - A low-incidence area. Br J Cancer. 1997;75(5):752-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9043036].
Yang Q, Khoury MJ, Rodriguez C, et al. Family history score as a predictor of breast cancer mortality: prospective data from the Cancer Prevention Study II, United States, 1982–1991. Am J Epidemiol. Apr. 1. 1998;147(7):652-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9554604].
Yang X-Z, Liu Y, Mi J, et al. Pre-clinical atherosclerosis evaluated by carotid artery intima-media thickness and the risk factors in children. Chin Med J (Engl). 2007;120(5):359-62. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17376303].
Yarnell J, Yu S, Patterson C, et al. Family history, longevity, and risk of coronary heart disease: the PRIME Study. Int J Epidemiol. Feb. 2003;32(1):71-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12690013].
Yasui Y, Newcomb PA, Trentham-Dietz A, et al. Familial relative risk estimates for use in epidemiologic analyses. Am J Epidemiol. Oct. 1. 2006;164(7):697-705. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16923773].
Yeh CY, Chiang JM, Wang JY, et al. Colonoscopic surveillance in asymptomatic persons with family history of colorectal cancer. Formos J Surg. 1999;32(3):111-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Yeung EH, Pankow JS, Astor BC, et al. Increased risk of type 2 diabetes from a family history of coronary heart disease and type 2 diabetes. Diabetes Care. Jan. 2007;30(1):154-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17192352].
Yip CH, bt Mohd Taib NA, Lau PC. Does a positive family history influence the presentation of breast cancer?. Asian Pac J Cancer Prev. Jan. 2008;9(1):63-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18439076].
Yokoe T, Takei H, Horiguchi J, et al. Family history in participants of breast cancer screening. Oncol Rep. 1997;4(5):973-6. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Yokoyama H, Kawai K, Ohishi M, et al. Familial predisposition to cardiovascular risk and disease contributes to cardiovascular risk and disease interacting with other cardiovascular risk factors in diabetes-Implication for common soil (JDDM 14). Atherosclerosis. 2008;201(2):332-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18423471].
Yologlu S, Sezgin AT, Sezgin N, et al. Determination of risk factors in obese and non-obese patients with coronary artery disease. Acta Cardiol. 2005;60(6):625-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16385924].
Yong MC, Zhou XJ, Lee SC. The importance of paternal family history in hereditary breast cancer is underappreciated by health care professionals. Oncology. 2003;64(3):220-6. Excluded because family history not collected. [pmid: 12697961].
Yoshinaga M, Nagashima M, Shibata T, et al. Who Is at Risk for Cardiac Events in Young Patients with Long QT Syndrome?. Circ J. 2003;67(12):1007-12. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14639015].
Young CA, Kumar S, Young MJ, et al. Excess maternal history of diabetes in Caucasian and Afro-origin non-insulin-dependent diabetic patients suggests dominant maternal factors in disease transmission. Diabetes Res Clin Pract. 1995;28(1):47-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 7587912].
Youssef AA, Valdez R, Elkasabany A, et al. Time-course of adiposity and fasting insulin from childhood to young adulthood in offspring of parents with coronary artery disease: the Bogalusa Heart Study. Ann Epidemiol. Nov. 2002;12(8):553-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12495828].
Yung AR, Phillips LJ, Yuen HP, et al. Risk factors for psychosis in an ultra high-risk group: Psychopathology and clinical features. Schizophr Res. 2004;67(2–3):131-42. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 14984872].
Zeegers MP, Schouten LJ, Goldbohm RA, et al. A compendium of familial relative risks of cancer among first degree relatives: A population-based study. Int J Cancer. 2008;123(7):1664-73. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18623131].
Zhang Y, Shu XO, Gao YT, et al. Family history of cancer and risk of lung cancer among nonsmoking Chinese women. Cancer Epidemiol Biomarkers Prev. Nov. 2007;16(11):2432-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 18006933].
Zheng YF, Saito T, Takahashi M, et al. Factors associated with intentions to adhere to colorectal cancer screening follow-up exams. BMC Public Health. 2006;6:272. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 17083746].
Zhou BS, Wang TJ, Guan P, et al. Indoor air pollution and pulmonary adenocarcinoma among females: a case-control study in Shenyang, China. Oncol Rep. Nov. 2000;7(6):1253-9. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 11032925].
Zhou WS, Hu ZP, Deng JG, et al. Comparative analysis of the risk factors of ischemic stroke in the middle-aged and youth. Chin J Clin Rehabil. 2005;9(9):184-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate.
Zhu S, Toyoshima H, Kondo T, et al. Short- and long-term reliability of information on previous illness and family history as compared with that on smoking and drinking habits in questionnaire surveys. J Epidemiol. Mar. 2002;12(2):120-5. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12033522].
Zimmerman M, McGlinchey JB, Young D, et al. Diagnosing major depressive disorder VII: family history as a diagnostic criterion. J Nerv Ment Dis. Sep. 2006;194(9):704-7. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16971823].
Ziogas A, Gildea M, Cohen P, et al. Cancer risk estimates for family members of a population-based family registry for breast and ovarian cancer. Cancer Epidemiol Biomarkers Prev. Jan. 2000;9(1):103-11. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10667470].
Ziv E, Shepherd J, Smith-Bindman R, et al. Mammographic breast density and family history of breast cancer. J Natl Cancer Inst. Apr. 2. 2003;95(7):556-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 12671024].
Zlot AI, Bland MP, Silvey K, et al. Influence of family history of diabetes on health care provider practice and patient behavior among nondiabetic Oregonians. Prev Chronic Dis. Jan. 2009;6(1):A27. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 19080033].
Zodpey SP, Tiwari RR, Kulkarni HR. Risk factors for haemorrhage stroke: A case-control study. Public Health. 2000;114(3):177-82. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 10878744].
Zureik M, Touboul PJ, Bonithon-Kopp C, et al. Differential association of common carotid intima-media thickness and carotid atherosclerotic plaques with parental history of premature death from coronary heart disease : the EVA study. Arterioscler Thromb Vasc Biol. Feb. 1999;19(2):366-71. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 9974420].
Zutavern A, Hirsch T, Leupold W, et al. Atopic dermatitis, extrinsic atopic dermatitis and the hygiene hypothesis: results from a cross-sectional study. Clin Exp Allergy. Oct. 2005;35(10):1301-8. Excluded because it does not meet all criteria for any one review question, although each of population, intervention and outcome criteria were met for the review questions in aggregate. [pmid: 16238789].