# Evidence Tables and Figures

Webtable 1 General data for cancer studies

Author Year | Study setting | Study design | n | Sub-groups measured | How/when FH obtained | Definition of outcome | How/when outcome ascertained
Ahn 2008 | Alpha-Tocopherol, Beta-Carotene Cancer Prevention Study, cohort of Finnish male smokers | Prospective cohort | 19,652 | male smokers and their 1DRs | questionnaire | histologically confirmed prostate cancer | national cancer registry and centralized record reviews
Byeon 2007 | Seoul, Korea Asymptomatic adults aged 20–90 y | prospective cohort | 860 | all subjects | questionnaire | histologically confirmed colon or rectal cancer, adenoma 10mm, villous adenoma, or adenoma with high grade dysplasia | screening colonoscopy
Cauley 2007 | women with osteoporosis, 80 y | analysis of MORE and CORE RCTs | 2,576 | all subjects followed for up to 8 y | self-completion questionnaire | incidence of breast cancer, histological confirmation | screening mammography, CBE
Cerhan 1996 | population-based, Iowa, U.S. | prospective cohort | 1,494 | males aged 67.9 ± 9.7 y | questionnaire | ICD oncology code 61.9 | passive followup through state cancer registry
Chen 2008 | health professionals in U.S. | cohort | 51,525 | age, clinical stage, Gleason score | questionnaire | histologically confirmed prostate cancer excluding stage T1a | self or proxy report through biennial survey
Denic 2001 | married women who are United Arab Emirates nationals, ages 40 to 65 y | cross-sectional | 1,445 | women, ages 40 to 65 y | interview | physician-confirmed breast cancer | self-report confirmed by medical records
Halapy 2005 | Ontario Breast Screening Program; women in Ontario | retrospective cohort | 115,460 | women aged 50–69y with no personal history of breast cancer or augmentation mammoplasty, and free of acute breast symptoms | interview | histologically confirmed invasive breast cancer | screening mammography, cancer registry
Kalish 2000 | Massachusetts Male Aging Study mean age 54.1 ± 8.4 y | prospective cohort | 1,149 | all subjects | questionnaire | prostate cancer, not further specified | PSA screening, medical record search, cancer registries
Kerlikowske 1997 | women accrued from a screening mammographic examination at the University of California San Francisco Mobile Mammography Screening Program | cross-sectional | 39,542 | women aged 30 y and older with no history of breast cancer and no previous mastectomies | interview | histologically confirmed invasive breast cancer | screening mammography, physician survey, pathology and radiology databases, SEER data
Mäkinen 2002 | Finnish prostate cancer screening trial, Finland, men aged 55 to 67 y | cross-sectional | 20,311 | males aged 55 to 67 y | questionnaire | histologically confirmed prostate cancer | PSA screening
Rodriguez 1997 | male participants in U.S. Cancer Prevention Study II | prospective cohort | 481,011 | all subjects | questionnaire | ICD-9 code 185 recorded as underlying cause of death | biennial personal inquiry, National Death Index
Sandhu 2001 | East Anglian component of the European Prospective Investigation into Cancer, UK, men and women aged 45–74 y | cross-sectional | 30,353 | men and women aged 40–79 y 40–49 y 50–59 y 60–69 y 70–79 y Women aged 40–79 y 40–49 y 50–59 y 60–69 y 70–79 y Men aged 40–79 y 40–49 y 50–59 y 60–69 y 70–79 y | questionnaire | registered in regional cancer registry with ICD-9 diagnosis codes 153.0–153.9, 154.0, 154.1 | regional cancer registry
Wei 2004 | patients from Nurses’ Health Study and Health Professionals Followup Study | combined prospective cohort | 134,365 | women men | questionnaire | histologically confirmed colon or rectal cancer | self or proxy report through biennial survey plus National Death Index

Abbreviations: 1DR=first degree relative; 2DR=second degree relative; CORE=Continuing Outcomes Relevant to Evista; CRC=Colorectal cancer; FH=Family History; ICD-9=International Classification of Diseases-Ninth Edition; MORE=Multiple Outcomes of Raloxifene Evaluation; n=number of subjects; PSA=prostate specific antigen; RCT=randomized controlled trial; y=years

Webtable 2 Predictive values associated with FH definitions for breast cancer in longitudinal analyses

FH category | Specific definition | Age criterion | Lineage criterion | Studies | Disease prevalence in study sample (%) | Prevalence of positive FH in study sample (%) | PPV for study sample | NPV for study sample | Most highly adjusted reported RR or equivalent^1^ (max length of FU)
C | ≥1 1DR female | N | N | Cauley | 2.5 | 12.5 | 0.05 | 0.98 | HR 2.83 (4–8y)
E | ≥1 1DR breast ≥50 OR 1 1DR ovarian | N | N | Halapy | 0.6 | 14.6 | 0.01 | 0.99 | 1.37 (12 mo)
E | ≥2 1DR breast and/or ovarian any age OR ≥1 1DR breast <50 y OR ≥1 1DR both breast and ovarian | Y | N | Halapy | 0.6 | 5.0 | 0.01 | 0.99 | 2.28 (12 mo)

Abbreviations: 1DR=first degree relative; FH=family history; FU=followup; mo=months; HR=hazard ratio; N=no; NPV=negative predictive value; PPV=positive predictive value; RR=relative risk; y=years; Y=yes

1 RR=relative risk, metric reported unless otherwise stated

Webtable 3 Predictive values associated with FH definitions for breast cancer cross-sectional analyses

FH category | Specific definition | Age criterion | Lineage criterion | Studies | Disease prevalence in study sample (%) | Prevalence of positive FH in study sample (%) | PPV for study sample | NPV for study sample | Most highly adjusted reported oR or equivalent^1^
C | ≥1 1DR | N | N | Denic | 5.4 | 3.0 | 0.09 | 0.95 | NR
C | ≥1 1DR | N | N | Kerlikowske | 0.7 | 9.9 | 0.01 | 0.99 | 1.7
E | consgs parents | N | N | Denic | 5.4 | 40.1 | 0.04 | 0.94 | 0.66 (RR)

Abbreviations: 1DR=first degree relative; consg=consanguineous; FH=family history; N=no; NPV=negative predictive value; NR=not reported; OR=odds ratio PPV=positive predictive value; RR=relative risk

1 OR=odds ratio, metric reported unless otherwise stated

Webtable 4 OR, HR and RR presented in each report for review question 1

Author Year | Family history | Outcome | Confounder adjustment | OR/HR/RR | OR/HR/RR | CI (low) | CI (high)
Ajlouni 2008 | diabetes (family history) | diabetes | | OR (multivariate) | 3.09 | 2.69 | 5.68
AhnJ 2008 | prostate cancer (1DR family history) | prostate cancer | age & trial intervention | RR | 1.91 | 1.49 | 2.47
AhnJ 2008 | prostate cancer (1DR family history) | prostate cancer (advanced disease (stage≥3) | age & trial intervention | RR | 4.16 | 2.67 | 6.49
Alford 2004 | asthma (paternal history) | asthma- current (seroatopy) | sex of the study child, parental education, parental smoking, multiple pet ownership, first-born status, and history of disease in other parent. | OR | 8.35 | 1.75 | 39.96
Annis 2005 | diabetes | diabetes (1DR relative) | NR | crude odds ratio | 5 | NR | NR
Bener 2005 | asthma (father) | asthma | NR | RR. | 2.3 | 1.9 | 2.7
Bener 2005 | asthma (mother) | asthma | NR | RR. | 2.1 | 1.8 | 2.4
Bergmann 1997 | atopy dermatitis (father history) | atopy - early | adjusted | OR | 4.92 | 2.34 | 10.3
Bindraban 2008 | diabetes (1DR relative) | diabetes | NR | OR (multi) | 2.7 | 1.8 | 4.2
Bjornholt 2000 | diabetes type 2 s(maternal) | diabetes type 2 | NR | HR | 2.65 | 1.64 | 4.25
Bjornholt 2000 | diabetes type 2 (paternal) | diabetes type 2 | NR | HR | 1.79 | 0.78 | 3.61
Bjornholt 2000 | diabetes type 2 (both) | diabetes type 2 | NR | HR | 6.89 | 2.18 | 21.7
Byeon 2007 | colorectal cancer (FH) | proximal advanced neoplasm without polyps | NR | OR | 6.0 | 1.3 | 26.6
Carlsson 2007 | diabetes(family) | LADA Type2 Type1 | age, sex | OR | 3.92 4.20 2.78 | 2.76 3.72 1.89 | 5.58 4.75 4.10
Cauley 2007 | breast cancer (FH) | breast cancer | NR | HR | 2.83 | 1.58 | 5.05
Cerhan 1999 | prostate cancer | prostate cancer (father or brother) | age, alcohol intake, nutrients or food | RR | 3.7 | 1.9 | 7.2
Cerhan 1999 | prostate cancer | prostate cancer (father | age, alcohol intake, nutrients or food | RR | 2.3 | 0.9 | 5.9
Cerhan 1999 | prostate cancer | prostate cancer (brother) | age, alcohol intake, nutrients or food | RR | 6.5 | 2.6 | 16
Chen 2008 | prostate cancer (father & brother) | prostate cancer | ethnicity, BMI, total calories, vigorous activity, cigarette smoking, consumption of tomato sauce, calcium, alpha linolenic acid, fish, red meat | RR | 2.34 | 1.76 | 3.12
Chatkin 2003 | asthma or allergy (family history) | current wheeze | adjusted | RR | 1.85 | 1.42 | 2.42
Chatkin 2005 | asthma (FH) | asthma | smoking during pregnancy and confounding variables? | RR | 2.8 | 1.5 | 5.1
Denic 2001 | breast cancer | breast cancer (consgs) | none | RR | 0.66 | 0.42 | 1.06
Djousse 2008 | MI (parental history) | heart failure in male physician | mutual adjustment for age (<45, 45–49, 50–54, 55–59, 60–64, 65 + y), smoking (never, past, and current smokers), body mass index (<25, 25–29, 30 + kg m–2), exercise (0, ≤ 1, 2–4, 5 + per week), alcohol (< 1, 1–4, 5–7, and 8 + drinks/week), breakfast cereals (≤ 1, 2–6, 7 + servings/week), cereal and history of hypertension, diabetes, left ventricular hypertrophy, atrial fibrillation, aspirin, fruit and vegetable consumption (< 3, 3–4, 5–6, 7–13, 14 + servings/week), and multivitamin use. | HR | 1.32 | 1.02 | 1.72
Dodani 2005 | coronary artery disease (FH) | coronary artery disease | NR | OR | 1.7 | 1.13 | 2.63
Ebbesson 1998 | diabetes | diabetes | age and obesity | OR | 4.4 | 1.8 | 10.7
Ebbesson 1998 | diabetes | Glucose intolerance | age and obesity | OR | 3.3 | 1.6 | 6.7
Garcia-Marcos 2005 | asthma (maternal & paternal) | atopic wheezing | male gender, mould stains, dog, cat | OR | 2.16 | 1.44 | 3.22
Gikas 2004 | diabetes (FH) | diabetes | age | OR | 6.91 | 5.11 | 9.34
Gillespie 2006 | allergic disease | wheezing | total number of people in the house, total number of rooms in the house, owning a pet, having a damp, musty smell, dampness or mold in the bedroom, having an open fireplace, maternal smoking, type of flooring in the bedroom | OR | 1.67 | 1.07 | 2.60
Gillespie 2006 | allergic disease | rash | total number of people in the house, total number of rooms in the house, owning a pet, having a damp, musty smell, dampness or mold in the bedroom, having an open fireplace, maternal smoking, type of flooring in the bedroom | OR | 2.10 | 1.22 | 3.61
Granstrom 2008 | breast cancer (mother) | breast cancer | NR | RR | 1.75 | 1.56 | 1.97
Halapy 2005 | breast cancer (strong FH) | breast cancer | age, HRT, prior screen | RR (rate ratio) | 2.14 | 0.91 | 4.99
Hariri 2006 | diabetes (FH) (moderate & high familial risk) | diabetes | all other demographic characteristic | OR | 3.6 | 2.8 | 4.7
Hariri 2006 | diabetes (high FH) | diabetes | demographic variables & BMI | OR | 4.6 | 1.9 | 11.3
Haron 2006 | diabetes (FH) | diabetes | NR | OR | 2.47 | 1.45 | 4.20
Hedlund 2006 | asthma symptom complex (FH) | asthma | socio economic class, occupational exposure to dust, gases or fumes, SOB | OR | 2.9 | 2.2 | 3.7
Hennis 2002 | diabetes (FH) | diabetes | adjusted (confounding variables) | OR | 2.85 | 2.39 | 3.40
Hilding 2006 | diabetes (FH) | diabetes in men | age, BMI, physical activity | OR | 3.1 | 1.7 | 5.6
Hilding 2006 | diabetes (FH) | diabetes in women | age, BMI, physical activity | OR | 1.7 | 1 | 3
Hippe 1999 | MI | MI | age, population study of origin, cholesterol BMI, diabetes (women) | RR | 1.42 | 0.12 | 1.79
Hippe 1999 | MI | MI | age, population study of origin, cholesterol BMI, diabetes (men) | RR | 1.30 | 1.11 | 1.52
Jorgensen 2002 | diabetes (FH) | diabetes (glucose tolerance) | age, sex | OR | 2.46 | 1.33 | 5.55
Jorgensen 2002 | diabetes (FH) | diabetes & IGT | age, sex | OR | 3.17 | 1.55 | 6.47
Jousilahti 1996 | premature coronary heart disease (either parent) | AMI | age (men) | RR | 1.61 | 1.36 | 1.89
Jousilahti 1996 | premature coronary heart disease (either parent) | AMI | age (women) | RR | 1.85 | 1.40 | 2.43
Jousilahti 1996 | premature coronary heart disease (either parent) | AMI | age, study year, cardiovascular risk factors (men) | RR | 1.54 | 1.31 | 1.82
Jousilahti 1996 | premature coronary heart disease (either parent) | AMI | age, study year, cardiovascular risk factors (women) | RR | 1.80 | 1.36 | 2.37
Jousilahti 1996 | premature coronary heart disease (either parent) | AMI | age, study year, and cardiovascular risk factors, and socioeconomic indicators (men) | RR | 1.55 | 1.31 | 1.83
Jousilahti 1996 | premature coronary heart disease (either parent) | AMI | age, study year, and cardiovascular risk factors, and socioeconomic indicators (women) | RR | 1.80 | 1.37 | 2.37
Jousilahti 1997 | stroke | stroke (any type) | age, study year, multifactorial double dagger adjustments | RR (Men) | 1.89 | 1.23 | 2.91
Jousilahti 1997 | stroke | stroke (any type) | age, study year, multifactorial double dagger adjustments | RR (women) | 1.80 | 1.17 | 2.75
Kadota 2008 | hypertension (FH) | all stroke | age, systolic BP, blood glucose, total cholesterol, smoking, drinking | HR | 1.36 | 0.96 | 1.93
Kalish 2000 | prostate cancer (F) prostate cancer (S) prostate cancer (B) | prostate cancer | age | RR | 2.59 3.87 3.29 | 1.27 1.74 1.82 | 5.29 8.57 5.9
Kalyoncu 2001 | atopy (family) | asthma current wheeze seasonal rhinitis | NR | POR | 1.99 2.18 2.20 | 1.14 1.55 1.69 | 3.47 3.06 2.86
Kerlikowske1997 | breast cancer (1DR relatives (mother, sister or daughter) | ductal carcinoma In situ | NR | OR (30–49 year old) | 2.4 | 1.1 | 4.9
Khan 2002 | NR | NR | NR | NR | NR | NR | NR
Kim 2008 | diabetes (family history) | diabetes | NR | RR | 2.12 | 1.49 | 3.00
Krakowiak 2007 | atopy | occupational asthma | NR | OR | 5.9 | 1.76 | 20.00
Kulig 2000 | NR | NR | NR | NR | NR | NR | NR
Kurukulaaratchy 2004 | asthma (maternal history) | atopic wheeze | NR | OR | 2.9 | 1.32 | 3.32
Kurukulaaratchy 2004 | asthma (paternal history) | atopic wheeze | NR | OR | 2.59 | 1.60 | 4.019
Lack 2003 | asthma (maternal) | peanut allergy | NR | OR | 1.55 | 0.72 | 3.32
Levitt 1999 | diabetes (Family history) | diabetes | NR | RR (risk ratio) | 2.31 | 1.42 | 3.77
London 2001 | allergy and asthma combined (parental history) | early-onset persistent asthma | NR | RR | 17.60 | 11 | 28.2
Lopez 1999 | NR | NR | NR | NR | NR | NR | NR
Magno 2008 | MI (parental) | CVD | age, exercise, parental history, LDL, HDL, hypertension, microalbuminuria, adiponectin | OR | 2.81 | 1.37 | 5.74
Makinen 2002 | prostate cancer (family history) | prostate – specific antigen | NR | RR (rate ratio) | 1.3 | 0.9 | 1.8
Makinen 2002 | prostate cancer (1DR relative(s)) | prostate – specific antigen | NR | RR | 1.26 | 0.87 | 1.82
Makinen 2002 | prostate cancer (father) | prostate – specific antigen | NR | RR | 1.18 | 0.76 | 1.53
Meigs 2000 | diabetes type 2 (mother) diabetes type 2 (father) diabetes type 2 (both) | diabetes type 2 | age | OR | 3.4 3.5 6.1 | 2.3 2.3 2.9 | 4.9 5.2 13.0
Melbostad 1998 | asthma (parents or sibling) | asthma (started in last 10 years) | NR | OR | 3.1 | 2.3 | 4.9
Montnemery 2000 | asthma | asthma | NR | OR | 3.71 | 3.06 | 4.51
Montnemery 2000 | chronic bronchitis/emphysema | asthma | NR | OR | 5.19 | 4.09 | 6.60
Morrison 2000 | stroke | subclinical stroke (cerebral infarct) | age, gender, race, multiple stroke risk factors | OR | 1.64 | 1.20 | 2.24
Morrison 2000 | stroke | subclinical stroke (cerebral infarct) | age, gender, race, | OR | 1.67 | 1.23 | 2.26
Motala 2008 | diabetes | diabetes | NR | OR | 3.5
Mohan 2003 | NR | NR | NR | NR | NR | NR | NR
Nakanishi 2003 | diabetes type 2 | diabetes type 2 | age, SBP, DBP, TG, HDL-c, NGT, IGT | HR (women) | 1.86 | 1.08 | 3.19
Nakanishi 2003 | diabetes type 2 | diabetes type 2 | age, SBP, DBP, TG, HDL-c, NGT, IGT, and BMI | HR (women) | 1.84 | 1.07 | 3.15
Nakanishi 2003 | diabetes type 2 | diabetes type 2 | age, SBP, DBP, TG, HDL-c, NGT, IGT, HOMA~R | HR (women) | 1.81 | 1.05 | 3.13
Nakanishi 2003 | diabetes type 2 | diabetes type 2 | age, SBP, DBP, TG, HDL-c, NGT, IGT, BMI, and HOMA~R | HR (women) | 1.79 | 1.04 | 3.10
Nyenwe 2003 | diabetes type 2 (FH) | diabetes type 2 | NR | OR | 9.45 | 3.49 | 35.53
Ones 1997 | asthma (1DR relatives) | asthma | NR | OR | 2.49 | 1.66 | 3.73
Ozdemir 2005 | diabetes (FH) | diabetes | NR | OR | 1.20 | 0.56 | 1.20
Park 1995 | asthma (FH) | asthma (Current) | sex, race, education | OR | 3.3 | 2.4 | 4.5
Park 1995 | asthma (FH) | asthma (physician reported) | sex, race, education | OR | 3.1 | 2.4 | 4.3
Patrzalek 2003 | allergy (maternal/paternal) | allergic disease | NR | OR | 11.2 | NR | NR
Piros 2000 | MI (mother or father | MI | NR | RR | 2.45 | 1.30 | 4.62
Pohlabeln 2007 | NR | NR | NR | NR | NR | NR | NR
Rahman 2008 | diabetes (parent & sibling) | diabetes | crude | OR | 3.30 | 1.61 | 6.75
Reinherz 2003 | psychiatric disorders (sibling) | depression | NR | OR adjusted | 2.88 | 1.20 | 6.97
Rodriguez 1997 | prostate cancer (≥1DR relatives) | prostate cancer | age at enrolment, race, years of e index, physical activity, intake of vegetables and fat, smoking status at study < vasectomy | RR (rate ratio) | 3.19 | 1.51 | 6.71
Rodriguez 1997 | prostate cancer (FH) | prostate cancer | age at enrolment, race, years of e index, physical activity, intake of vegetables and fat, smoking status at study < vasectomy | RR (rate ratio) | 1.60 | 1.31 | 1.97
Sandhu 2001 | colorectal cancer | colorectal cancer | age, smoking | OR (women) | 2.77 | 1.46 | 5.26
Sandhu 2001 | colorectal cancer (one or more 1DR relatives) | colorectal cancer | age, smoking | OR (women) | 2.11 | 1.26 | 3.54
Sandhu 2001 | colorectal cancer (two or more 1DR relatives) | colorectal cancer | age, smoking | OR (women) | 5.29 | 1.63 | 17.17
Saquib 2005 | NR | NR | NR | NR | NR | NR | NR
Scheuner 2006 | CHD (1DR relatives) | CHD | age, race, marital status, education, income, self-reported obesity, hypercholesterolemia, hypertension | OR | 3.8 | 2.3 | 6.2
Scheuner 2006 | stroke (1DR relatives) | stroke | age, race, marital status, education, income, self-reported obesity, hypercholesterolemia, hypertension | OR | 1.5 | 1 | 2.3
Sesso 2001 | MI (parental history maternal and/or parental) | CVD, MI, stroke | age, | RR (women, MI) | 2.86 | 1.73 | 4.73
Shera 2007 | NR | NR | NR | NR | NR | NR | NR
Sugimori 1998 | diabetes | diabetes | NR | HR | 1.65 | 1.16 | 2.36

Abbreviations: 1DR=first degree relative; AMI=acute myocardial infarction; B=any family history; BMI=body mass index; BP=blood pressure; CI=confidence interval; CHD=coronary heart disease; CVD=cardiovascular disease; DBP=diastolic blood pressure; F=father’s side of family; FH=family history; HDL=high density lipoprotein; HDL-C=high density lipoprotein-cholesterol; HOMA-R=homeostasis model assessment; HR=hazard ratio, HRT=hormone replacement therapy; IGT=impaired glucose tolerance; LADA=latent autoimmune diabetes in adults; LDL=low density lipoprotein; MI=myocardial infarction; multi=multivariate; NGT=normal glucose tolerance; NR=not reported; OR=odds ratio; POR=prevalence odds ratio; RR=relative risk; S=sibling; SBP=systolic blood pressure; SOB=shortness of breath; TG=triglycerides

Webtable 5 Quality items for cancer studies for review question 1

Author Year | Same outcome ascertainment, irrespective of FH (outcome information bias) | Outcome ascertainment blind to FH (outcome information bias) | Same FH ascertainment, irrespective of disease status (exposure information bias) | FH ascertainment blind to disease status (exposure information bias) | Exclusion of cases at inception (cohort) (misclassification) | Adequate followup (cohort) (selection bias) | Representative sampling (cross-sectional) (selection bias) | Adequate response rate (cross-sectional) (selection bias)
Breast cancer
Cauley 2006 | Yes | Yes | Yes | Yes | Yes | At least 80% followup | Not applicable (longitudinal design) | Not applicable (longitudinal design)
Halapy 2005 | Yes | Yes | Unclear | Yes | Yes | At least 80% followup | Not applicable (longitudinal design) | Not applicable (longitudinal design)
Denic 2001 | Unclear | Unclear | Yes | No | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Unclear | Response rate less than 80%, inadequate or missing description of non-participants
Kerlikowske 1997 | Yes | Yes | Unclear | Yes | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Yes (probability sampling) | Yes, response rate at least 80%
CRC
Byeon 2007 | Yes | Unclear | Yes | Yes | Not applicable (cross sectional design) | Not applicable (cross sectional design) | No (non-probability sampling) | Unclear
Sandhu 2001 | Yes | No | Yes | No | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Yes (probability sampling) | Unclear
Wei 2004 | Yes | Unclear | Yes | Unclear | Yes | Unclear | Not applicable (longitudinal design) | Not applicable (longitudinal design)
Prostate cancer
Ahn 2008 | Yes | Yes | Yes | Yes | Yes | Unclear | Not applicable (longitudinal design) | Not applicable (longitudinal design)
Cerhan 1996 | Yes | Yes | No | Yes | Yes | at least 80% followup | Not applicable (longitudinal design) | Not applicable (longitudinal design)
Chen 2008 | Yes | Unclear | Yes | Unclear | Unclear | Unclear | Not applicable (longitudinal design) | Not applicable (longitudinal design)
Kalish 2000 | Yes | No | Yes | Yes | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Yes (probability sampling) | Unclear
Makinen 2002 | Yes | Unclear | Yes | Yes | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Yes (probability sampling) | Response rate less than 80%, inadequate or missing description of non-participants
Rodriguez 1997 | Yes | Unclear | Yes | Yes | Yes | Unclear | Not applicable (longitudinal design) | Not applicable (longitudinal design)

Webtable 6 Predictive values associated with FH definitions for colorectal cancer in longitudinal analyses

FH category | Specific definition | Age criterion | Lineage criterion | Studies | Disease prevalence in study sample (%) | Prevalence of positive FH in study sample (%) | PPV for study sample | NPV for study sample | Most highly adjusted reported RR or equivalent^1^ (max length of FU)
C | ≥1 1DR | N | N | Wei, M | 1.3^1^ | 8.5^1^ | 0.02^1^ | 0.99^2^ | colon 1.86^3^ rectum 1.33^3^
C | ≥1 1DR | N | N | Wei, F | 1.0^1^ | 7.9^1^ | 0.02^1^ | 0.99^2^ | colon 1.86^3^ rectum 1.33^3^

Abbreviations: 1DR=first degree relative; F=female; FH=family history; FU=followup; M=male; NPV=negative predictive value; N=No; PPV=positive predictive value; RR=relative risk

1 RR=relative risk, metric reported unless otherwise stated

2 Colon and rectal cancer outcomes combined

3 Reported for males and females combined

Webtable 7 Predictive values associated with FH definitions for colorectal cancer in cross-sectional analyses

FH category | Specific definition | Age criterion | Lineage criterion | Studies | Disease prevalence in study sample (%) | Prevalence of positive FH in study sample (%) | PPV for study sample | NPV for study sample | Most highly adjusted reported OR or equivalent^1^
C | ≥1 1DR | N | N | Sandhu, M&F | 0.5 | 6.8 | 0.01 | 1.00 | 2.32
C | ≥1 1DR | N | N | Byeon, M&F | 4.5 | 12.7 | 0.07 | 0.96 | 3.2
C | ≥1 1DR | N | N | Sandhu, M | 0.6 | 6.1 | 0.01 | 0.99 | 1.87
C | ≥1 1DR | N | N | Sandhu, F | 0.4 | 7.4 | 0.01 | 1.00 | 2.77
C | ≥1 1DR | N | N | Sandhu, M&F, premature(<50) | 0.0 | 5.1 | 0.00 | 1.00 | -
C | ≥1 1DR | N | N | Sandhu, M&F, premature(<60) | 0.2 | 6.1 | 0.00 | 1.00 | 1.75
C | ≥1 1DR | N | N | Sandhu, M, premature (<60) | 0.3 | 5.6 | 0.00 | 1.00 | -
C | ≥1 1DR | N | N | Sandhu M, premature (<50) | 0.0 | 4.2 | 0.00 | 1.00 | -
C | ≥1 1DR | N | N | SandhuF, premature (<60) | 0.1 | 6.5 | 0.00 | 1.00 | 3.62
C | ≥1 1DR | N | N | Sandhu, F, premature (<50) | 0.0 | 5.7 | 0.00 | 1.00 | -
C | ≥2 1DR | N | N | Sandhu, M&F | 0.5 | 0.3 | 0.03 | 1.00 | 5.29
C | ≥1 1DR, onset <65 | Y | N | Sandhu,M&F | 0.5 | 2.4 | 0.02 | 1.00 | 3.26
C | ≥1 1DR, onset <45 | Y | N | SandhuM&F | 0.5 | 0.3 | 0.02 | 1.00 | 4.93

Abbreviations: 1DR=first degree relative; F=female; FH=family history; M=male; N=no; NPV=negative predictive value; NR=not reported; OR=odds ratio PPV=positive predictive value; Y=yes

1 OR=odds ratio, metric reported unless otherwise stated

Webtable 8 Predictive values associated with FH definitions for prostate cancer in longitudinal analyses

FH category | Specific definition | Age criterion | Lineage criterion | Studies | Disease prevalence in study sample (%) | Prevalence of positive FH in study sample (%) | PPV for study sample | NPV for study sample | Most highly adjusted reported OR or equivalent^1^
B | father | N | N | Cerhan | 6.5 | 3.0 | 0.13 | 0.94 | 2.3 (6–8 y)
B | ≥1 brother | N | N | Cerhan | 6.5 | 1.8 | 0.26 | 0.94 | 6.5 (6–8 y)
B | father and/or brother | N | N | Chen | 8.7 | 12.4 | 0.14 | 0.92 | 1.83 (10y)
C | ≥1 1DR | N | N | Rodriguez | 0.4 | 3.0 | 0.01 | 1.00 | 1.6 (9 y)
C | ≥1 1DR | N | N | Ahn | 5.7 | 3.0 | 0.11 | 0.95 | 1.91 (12 y)
C | ≥1 1DR | N | N | Cerhan | 6.5 | 4.8 | 0.18 | 0.94 | 3.7 (6–8 y)
C | ≥2 1DR | N | N | Rodriguez | 0.4 | 0.1 | 0.03 | 1.00 | 3.19 (9 y)

Abbreviations: 1DR=first degree relative; FH=family history; FU=followup; NPV=negative predictive value; N=No; PPV=positive predictive value; RR=relative risk; y=years

1 RR=relative risk, metric reported unless otherwise stated

Webtable 9 Predictive values associated with FH definitions for prostate cancer in cross-sectional analyses

FH category | Specific definition | age criterion | Lineage criterion | Studies | Disease prevalence in study sample (%) | Prevalence of positive FH in study sample (%) | PPV for study sample | NPV for study sample | Most highly adjusted reported OR or equivalent^1^
A | any relative | N | N | Kalish | 5.0 | 9.6 | 0.14 | 0.96 | 3.29
B | Father | N | N | Makinen | 2.4 | 3.5 | 0.03 | 0.98 | 1.18
B | ≥1 brother | N | N | Makinen | 2.4 | 1.3 | 0.04 | 0.98 | 1.57
C | ≥1 1DR | N | N | Makinen | 2.4 | 4.7 | 0.03 | 0.98 | 1.26
C | ≥1 1DR, onset <60 | Y | N | Makinen | 2.4 | 0.4 | 0.03 | 0.98 | 1.40
D | ≥1 1DR or 2DR | N | N | Makinen | 2.4 | 7.7 | 0.03 | 0.98 | 1.27
E | paternal grandfather or ≥1 paternal uncle | N | Y | Makinen | 2.4 | 1.7 | 0.02 | 0.98 | 0.97
E | maternal grandfather or ≥1 maternal uncle | N | Y | Makinen | 2.4 | 1.8 | 0.03 | 0.98 | 1.14

Abbreviations: 1DR=first degree relative; FH=family history; N=no; NPV=negative predictive value; NR=not reported; OR=odds ratio PPV=positive predictive value; Y=yes

1 OR=odds ratio, metric reported unless otherwise stated

Webtable 10 General data for cardiovascular and stroke studies

Author Year | Study setting | Study design | n | Sub-groups measured | How/when FH obtained | Definition of outcome | How/when outcome ascertained
Djousse 2008 | association between parental history of MI & incident HF in PHS, U.S. | RCT | 20187 | age | questionnaire | independently validated heart failure | annual survey
Dodani 2005 | Aga Khan University Hospital in Karachi, Pakistan recruited Pakistanis >18 y | cross-sectional study | 580 | men and women >18 y; mean age of 46 y with 78.5% male | questionnaire | ≥1 of documented myocardial infarction, angiographically confirmed coronary artery disease, or history of typical angina with positive treadmill test | clinical evaluation
Hippe 1999 | Copenhagen Centre for Prospective Population Studies, men and women, age 20 to 93 y | prospective cohort | 24,664 | women men | questionnaire | ICD-8 code 410 | search of national death register and national hospital discharge register
Jousilahti 1997 | random sample of 25 to 64 y in Finland | cohort | 14,371 | gender type of stroke | questionnaire | fatal or non-fatal stroke coded to ICD-8 432, 433, 436 or ICD-9 431, 432 | national death register, national hospital discharge register
Jousilahti 1996 | Finland, males and females, 30 to 59 y | prospective cohort | 15,620 (7,605 males, 8,015 females) | Male Female | questionnaire | cause of death coded to ICD-8 410-414 or hospitalizations coded to ICD-8 410-411 | national death register, national hospital discharge register
Kadota 2008 | cohort study of the National Survey on Circulatory Disorders, Japan | longitudinal prospective cohort | 8,037 | gender | Survey, not further specified | underlying cause of death coded to ICD-9 430-438, ICD-10 I60-I69 | national death register
Magno 2008 | community dwelling Filipino American women aged 40 to 86 y | cross-sectional | 266 | all subjects | questionnaire | hospitalization for CVD episodes or procedures OR ECG abnormalities (Minnesota codes 1.1, 1.2, 1.3, 4.1–4.4, 5.3 or 7.1.1), Rose angina, self-report of physician-diagnosed myocardial infarction | clinical evaluation
Morrison 2000 | the Atheroscleros is Risk in Communities Study, Houston, Texas, aged 45 to 64 y | cohort | 15,792 | cerebral MRI on 1931 subjects ≥55 y | interview | clinical ischemic stroke not further specified | review of hospital records, annual survey, death certificates
Piros 2000 | railway engine drivers, Sweden, males aged 25–59 y | prospective cohort | 1,409 | males aged 25 to 59 y | Not specified, likely questionnaire | hospital-diagnosed myocardial infarction with ≥2 of typical chest pain, typical enzyme changes, ECG findings OR autopsy evidence OR sudden death with history of ischemic symptoms and no evidence for non-coronary death | hospital-diagnosed MI, national register on diseases
Scheuner 2006 | HealthStyles 2003 survey administered to American adults (male and female) with a mean age of 48.8 y | cross-sectional study | 3,956 | stratified random sample of participants from 2003 survey | questionnaire | positive report of doctor-diagnosed CHD | questionnaire responses
Sesso 2001 | The Physician’s Health Study (PHS) trial in the prevention of CVD and cancer | prospective cohort study | men n=20,515 Women n=37,985 | U.S. male physicians aged 40–84 y female health professionals aged ≥45 y | questionnaire | events meeting WHO criteria for myocardial infarction, confirmed by independent committee | annual survey

Abbreviations: 1D=1DR; 1DR=first degree relative; 2DR=second degree relative; AMI=acute myocardial infarction; CAD=coronary artery disease; CHD=congestive heart disease; CVD=cardiovascular disease; FH=family history; FPG=fasting plasma glucose; HDL=high density lipoprotein; HF=heart failure; LDL=low density lipoprotein; MI=myocardial infarction; MRI=magnetic resonance imaging; n=number of subjects; PHS=physician’s health study; RCT=Randomized Controlled Study; TIA=transient ischemic attack; U.S.=United States of America; WHO=World Health Organization; y=years

Webtable 11 Predictive values associated with FH definitions for CHD in longitudinal analyses

FH category | Specific definition | Age criterion | Lineage criterion | Studies | Disease prevalence in study sample (%) | Prevalence of positive FH in study sample (%) | PPV for study sample | NPV for study sample | Most highly adjusted reported RR or equivalent^1^ (max length of FU)
B | ≥1 parent | N | N | Djousse, M | 5.1 | 31.1 | 0.06 | 0.69 | NR
B | ≥1 parent | N | N | Sesso, M | 3.2 | 34.5 | 0.04 | 0.66 | NR
B | ≥1 parent | N | N | Hippe, M | 9.0 | 19.3 | 0.11 | 0.81 | 1.30 (12 y)
B | ≥1 parent | N | N | Sesso, F | 0.4 | 34.1 | 0.01 | 0.66 | NR
B | ≥1 parent | N | N | Hippe, F | 4.3 | 23.2 | 0.05 | 0.77 | 1.42 (12 y)
B | father | N | N | Sesso, M | 3.2 | 28.8 | 0.04 | 0.71 | 1.58 (13 y)
B | father | N | N | Piros, M | 3.0 | 2.2 | 0.06 | 0.98 | 4.13 (10 y)
B | father | N | N | Sesso, F | 0.4 | 26.2 | 0.00 | 0.74 | 0.93 (6 y)
B | mother | N | N | Sesso, M | 3.2 | 9.1 | 0.05 | 0.91 | 2.14 (13 y)
B | mother | N | N | Piros, M | 3.0 | 2.7 | 0.08 | 0.97 | 3.55 (10 y)
B | mother | N | N | Sesso, F | 0.4 | 12.3 | 0.01 | 0.88 | 1.76 (6 y)
B | both parents | N | N | Sesso, M | 3.2 | 3.5 | 0.05 | 0.97 | 1.98 (13 y)
B | both parents | N | N | Sesso, F | 0.4 | 4.4 | 0.01 | 0.96 | 2.49 (6 y)
B | ≥1 parent, onset <65y | Y | N | Djousse, M | 5.1 | 15.2 | 0.05 | 0.85 | NR
B | ≥1 parent, onset <60y | Y | N | Djousse, M | 5.1 | 9.7 | 0.05 | 0.90 | NR
B | ≥1 parent, onset <60y | Y | N | Jousilahti, M | 10.4 | 22.4 | 0.13 | 0.78 | 1.55 (12 y)
B | ≥1 parent, onset <60y | Y | N | Jousilahti, F | 4.4 | 24.6 | 0.09 | 0.77 | 1.80 (12 y)
B | ≥1 parent, onset <55y | Y | N | Djousse, M | 5.1 | 5.7 | 0.05 | 0.94 | 1.32 (20 y)^2^
B | father, onset <60y | Y | N | Jousilahti, M | 10.4 | 16.5 | 0.13 | 0.84 | 1.65 (12 y)
B | father, onset <60y | Y | N | Jousilahti, F | 3.2 | 17.4 | 0.03 | 0.83 | 1.58 (12 y)
B | mother, onset<60y | Y | N | Jousilahti, M | 10.4 | 8.5 | 0.12 | 0.92 | 1.34 (12 y)
| | | | Jousilahti, F | 3.2 | 10.4 | 0.05 | 0.90 | 2.1 (12 y)
B | both parents, onset <60y | Y | N | Jousilahti, M | 10.4 | 2.6 | 0.12 | 0.97 | 1.37 (12 y)
B | both parents, onset <60y | Y | N | Jousilahti, F | 3.2 | 3.1 | 0.03 | 0.97 | 1.27 (12 y)

Abbreviations: 1DR=first degree relative; CHD=coronary heart disease; F=female; FH=family history; FU=followup; M=male; N=no; NPV=negative predictive value; PPV=positive predictive value; RR=relative risk; y=years; Y=yes

1 RR=relative risk, metric reported unless otherwise stated

2 Reference=no family history

Webtable 12 Predictive values associated with FH definitions for CHD in cross-sectional analyses

FH category | Specific definition | Age criterion | Lineage criterion | Studies | Disease prevalence in study sample (%) | Prevalence of positive FH in study sample (%) | PPV for study sample | NPV for study sample | Most highly adjusted reported OR or equivalent
B | ≥1 parent | N | N | Scheuner, M&F premature | 4.5 | 13.2 | 0.08 | 0.96 | 3.8
B | ≥1 parent | N | N | Magno, F | 20.7 | 25.2 | 0.31 | 0.83 | 2.81
B | father | N | N | Scheuner, M&F, premature | 4.5 | 9.3 | 0.09 | 0.96 | NR
B | mother | N | N | Scheuner, M&F, premature | 4.5 | 6.3 | 0.10 | 0.96 | NR
B | ≥1 sibling | N | N | Scheuner, M&F, premature | 4.5 | 5.3 | 0.16 | 0.96 | 3.1
B | both parents | N | N | Scheuner, M&F, premature | 4.5 | 2.4 | 0.16 | 0.96 | 6.2
B | ≥1 parent + ≥1 sibling | N | N | Scheuner, M&F, premature | 4.5 | 2.6 | 0.13 | 0.96 | 5.0
C | ≥1 1DR | N | N | Scheuner, M&F, premature | 4.5 | 38.8 | 0.08 | 0.98 | 3.8
C | ≥2 1DR | N | N | Scheuner, M&F, premature | 4.5 | 5.1 | 0.14 | 0.96 | 5.1
C | ≥1 1DR, early onset | Y | N | Scheuner, M&F, premature | 4.5 | 9.3 | 0.11 | 0.96 | 5.0
D | ≥1 1DR + ≥1 2DR, any age | N | N | Scheuner, M&F, premature | 4.5 | 18.7 | 0.10 | 0.97 | 4.5
E | fr, br, grfr<55, mr, sis, gmr<65 | Y | N | Dodani, M&F | 19.1 | 49.5 | 0.23 | 0.85 | 1.7

Abbreviations: 1DR=first degree relative; 2DR=second degree relative; br=brother; CHD=coronary heart disease; F=female; FH=family history; fr=father; grfr=grandfather; grmr=grandmother; M=male; mr=mother; N=no; NPV=negative predictive value; NR=not reported; OR=odds ratio; PPV=positive predictive value; sis=sister; Y=yes

Webtable 13 Quality items for CVD and stroke studies for review question 1

Author Year | Same outcome ascertainment, irrespective of FH (outcome information bias) | Outcome ascertainment blind to FH (outcome information bias) | Same FH ascertain ment, irrespective of disease status (exposure information bias) | FH ascertainment blind to disease status (exposure information bias) | Exclusion of cases at inception (cohort) (misclassification) | Adequate followup (cohort) (selection bias) | Representative sampling (cross-sectional) (selection bias) | Adequate response rate (cross-sectional) (selection bias)
CVD
Jousilahti 1996 | Yes | Yes | Yes | Yes | Yes | At least 80% followup | Not applicable (longitudinal design) | Not applicable (longitudinal design)
Sesso 2001 | Yes | Unclear | Yes | Yes | Yes | Unclear | Not applicable (longitudinal design) | Not applicable (longitudinal design)
Piros 2000 | Yes | Unclear | Unclear | Unclear | Unclear | At least 80% followup | Not applicable (longitudinal design) | Not applicable (longitudinal design)
Hippe 1999 | Yes | Yes | Yes | Yes | Yes | Unclear | Not applicable (longitudinal design) | Not applicable (longitudinal design)
Djousse 2008 | Yes | Unclear | Yes | Yes | Yes | Unclear | Not applicable (longitudinal design) | Not applicable (longitudinal design)
Magno 2008 | Yes | No | Yes | No | Not applicable (cross-sectional design) | Not applicable (cross-sectional design) | No (non-probability sampling) | Unclear
Dodani 2005 | Yes | No | Unclear | No | Not applicable (cross sectional design) | Not applicable (cross sectional design) | No (non-probability sampling) | Unclear
Scheuner 2006 | Yes | No | Yes | No | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Yes (probability sampling) | Response rate less than 80%, inadequate or missing description of non-participants
Stroke
Morrison 2000 | Unclear | Unclear | Unclear | Yes | Yes | Unclear | Not applicable (longitudinal design) | Not applicable (longitudinal design)
Jousilahti 1997 | Yes | Yes | Yes | Yes | Yes | Unclear | Not applicable(longitudinal design) | Not applicable (longitudinal design)
Kadota 2008 | Yes | Yes | Yes | Yes | Yes | At least 80% followup | Not applicable (longitudinal design) | Not applicable (longitudinal design)

Abbreviations: 1DR=first degree relative; CHD=coronary heart disease; F=female; FH=family history; FU=followup; M=male; N=no; NPV=negative predictive value; PPV=positive predictive value; RR=relative risk; y=years; Y=yes

Webtable 14 Predictive values associated with FH definitions for stroke in longitudinal analyses

FH category | Specific definition | Age criterion | Lineage criterion | Studies | Disease prevalence in study sample (%) | Prevalence of positive FH in study sample (%) | PPV for study sample | NPV for study sample | Most highly adjusted reported RR or equivalent^1^ (max length of FU)
B | ≥1 parent | N | N | Morrison | 1.9 | 29.1 | 0.02 | 0.98 | 1.64 (5 y)
B | ≥1 parent | N | N | Jousilahti, M, premature disease | 3.4 | 4.9 | 0.07 | 0.97 | 1.89 (7–12 y)
B | ≥1 parent | N | N | Kadota, M | 3.9 | 20.4 | 0.03 | 0.96 | 0.73 (19 y)
B | ≥1 parent | N | N | Jousilahti, F, premature disease | 2.6 | 6.2 | 0.06 | 0.98 | 1.80 (7–12 y)
B | ≥1 parent | N | N | Kadota, F | 2.7 | 20.7 | 0.03 | 0.97 | 1.38 (19 y)
B | father | N | N | Jousilahti, M, premature disease | 3.4 | 2.1 | 0.08 | 0.97 | 2.17(7–12 y)
B | father | N | N | Jousilahti, F, premature disease | 2.6 | 2.8 | 0.06 | 0.98 | 2.15 (7–12 y)
B | mother | N | N | Jousilahti, M, premature disease | 3.4 | 2.6 | 0.07 | 0.97 | 1.83 (7–12 y)
B | mother | N | N | Jousilahti, F, premature disease | 2.6 | 3.2 | 0.06 | 0.98 | 1.67 (7–12 y)

Abbreviations: 1DR=first degree relative; F=female; FH=family history; FU=followup; M=male; N=no; NPV=negative predictive value; PPV=positive predictive value; RR=relative risk; y=years

1 RR=relative risk, metric reported unless otherwise stated

Webtable 15 General data for diabetes studies

Author Year | Study setting | Study design | n | Sub-groups measured | How/when FH obtained | Definition of outcome | How/when outcome ascertained
Ajlouni 2008 | study of diabetes and performance risk score in Hindustani Surinamese, African Surinamese, and Dutch aged 35–60, Amsterdam Netherland | cross-sectional | 1,415 | age | interview | clinical evaluation | clinical evaluation
Annis 2005 | National Health and Nutrition Examination Survey (NHANES) of the civilian, not institutionalized U.S. population over the age of 20 y | retrospective cohort | 10,283 10,067 analysed | men and women ^3^20y | interview | self-report of physician diagnosis | survey
Bindraban 2008 | study of Jordanian aged 25 y and above, Jordan | cross-sectional | 1,121 | Gender, age | interview | fasting glucose>7.0mmol/l or self-reported diabetes | clinical evaluation
Bjornholt 2000 | accruement from a cardiovascular screening survey in Oslo, Norway | prospective followup study | 1,947 | healthy non-diabetic men aged 40 to 59 years with fasting blood glucose levels <110 mg/dl at baseline | questionnaire | diabetes confirmed from ≥ 2 of: fasting glucose 120 mg/dl/2-h glucose ≥ 180mg/dl OR hospital diagnosis of diabetes OR death coded to ICD-9 diabetes codes | clinical evaluation
Boer 1996 | Zutphen Elderly Study - a longitudinal study on the risk factors for chronic diseases | cross-sectional study | 468 | men aged 69 to 90 y | interview | fasting glucose ≥ 7.8mmol/l OR 2-h glucose ≥ 11.1mmol/l or known diabetes | clinical evaluation
Carlsson 2007 | Nord-Trøndelag Health Study, Norway | cross-sectional study | 64,498 | men and women >20 y | questionnaire | incompletely described but likely self-report of physician diagnosis | clinical evaluation
Ebbesson 1998 | residents of Alaska, U.S. men and women aged ≥ 25 y | prospective cohort | 391 | men and women aged ≥ 25 y women only men only | interview | fasting glucose ≥ 7.8 mmol/l or WHO 1985 criteria | clinical evaluation
Gikas 2004 | Salamis, Greece, age 20–94y | cross-sectional | 2,805 | all subjects | interview | self-report of doctor diagnosis of diabetes or hypoglycemic therapy | survey
Hariri 2006 | National Health and Nutrition Examination Survey, United States population, males and non-pregnant females ≥ 20 y | cohort study | 3,823 | non-pregnant adults, ≥ 20 y | interview | self-report of physician diagnosis OR fasting glucose ≥ 126mg/dl | survey and clinical evaluation
Hariri 2006 | HealthStyles 2004 mail survey of health-related attitudes and beliefs | cross-sectional study | 4,345 | U.S. adult population, aged 18 and over | questionnaire | self-report of physician diagnosis of diabetes | survey
Haron 2006 | Northern Israeli Circassian men and women, aged 35 y and older | retrospective cohort | 740 | men and women >35y | interview | hypoglycemic therapy OR fasting glucose ≥ 126mg/dl on two occasions OR 2-hr glucose ≥ 200mg/dl | clinical evaluation
Hilding 2006 | Stockholm Diabetes Prevention Programme, men and women aged 35 to 56 y from the outskirts of Stockholm | cross-sectional study | 7,949 total 3,128 men and 4,821 women | men and women, aged 35–56y, half with a FH of diabetes | questionnaire | WHO 1998 criteria | clinical evaluation
Meigs 2000 | Framingham Offspring Study aged 12 to 58 y at baseline | cohort | 2,527 | all subjects | Original clinical evaluation data from first generation of parent-offspring cohort study | fasting glucose ≥ 7.8mmol/l or self-report of hypoglycemic therapy | clinical evaluation
Mohan 2003 | Chennai Urban Population Study, Chennai, India, men and women aged >= 20 | prospective cohort | 1,262 | men and women aged >= 20 y | interview | hypoglycemic therapy OR fasting glucose ≥ 126mg/dl OR 2-hr glucose ≥ 200mg/dl | clinical evaluation
Nakanishi 2003 | Japanese-Americans, Hawaii and Los Angeles, CA, U.S. | prospective Cohort | 403 men 557 women | men aged 61.2±1.9 y (FH+); 67.2±1.0 y (FH−) women aged 60.7±1.4 y (FH+); 61.9±0.8 y (FH−) | survey, not further specified | 1998 WHO criteria for diabetes on basis of oral GTT | clinical evaluation
Nyenwe 2003 | Nigeria, age >40y | cross-sectional | 491 | all subjects | questionnaire | WHO 1999 criteria or self-report of physician diagnosis | clinical evaluation
Rahman 2008 | European Prospective Investigation (EPIC) of Cancer-Norfolk, age 40 to 79 y | prospective cohort | 24,495 | all subjects | questionnaire | incompletely described but likely physician diagnosis OR receiving hypoglycemic therapy OR elevated non-fasting glucode OR elevated HBA1c | self-report at followup, hospital and family practice registers, death registration, hypoglycemic prescription records
Shera 2007 | random sample of subjects >24 y in Pakistan | cross-sectional | 5,433 | gender | unclear | fasting glucose >140 mg/dl or 2 h glucose >200 mg/dl | clinical evaluation

Abbreviations: 1DR=first degree relative; 2DR=second degree relative; DM=diabetes mellitus; EPIC=European prospective investigation of cancer; FH=family history; FPG=fasting plasma glucose; GTT=glucose tolerance test; LPG=level of plasma glucose; n=number of subjects; OGTT=oral glucose tolerance test; WHO=World Health Organization; y=years

Webtable 16 Predictive values associated with FH definitions for diabetes in longitudinal analyses

FH category | Specific definition | Age criterion | Lineage criterion | Studies | Disease prevalence in study sample (%) | Prevalence of positive FH in study sample (%) | PPV for study sample | NPV for study sample | Most highly adjusted reported RR or equivalent^1^ (max length of FU)
B | ≥1 parent | N | N | Meigs, M&F | 8.7 | 23.7 | 0.17 | 0.94 | NR
B | ≥1 parent | N | N | Bjornholt, M | 7.3 | 10.6 | 0.15 | 0.94 | NR
B | father | N | N | Meigs, M&F | 8.7 | 13.2 | 0.16 | 0.92 | 3.5 (20 y)
B | father | N | N | Bjornholt, M | 7.3 | 3.9 | 0.13 | 0.93 | 1.79 (22 y)^2^
B | mother | N | N | Meigs, M&F | 8.7 | 12.1 | 0.20 | 0.93 | 3.4 (20 y)
B | mother | N | N | Bjornholt, M | 7.3 | 7.2 | 0.16 | 0.93 | 2.65 (22 y)^2^
B | both parents | N | N | Meigs, M&F | 8.7 | 1.7 | 0.26 | 0.92 | 6.1 (20 y)
B | both parents | N | N | Bjornholt, M | 7.3 | 0.5 | 0.30 | 0.93 | 6.89 (22 y)^2^
C | ≥1 1DR | N | N | Boer, M | 16.2 | 9.3 | 0.38 | 0.86 | 3.9 (5 y)
C | ≥1 1DR | N | N | Nakanishi, M | 14.4 | 15.1 | 0.20 | 0.87 | 1.56 (7 y)
C | ≥1 1DR | N | N | Nakanishi, F | 12.2 | 16.3 | 0.21 | 0.89 | 1.79 (7 y)
C | ≥1 parent or sibling | N | N | Rahman, M&F | 1.3 | 12.2 | 0.02 | 0.99 | 1.53 (5 y)
C | ≥1 parent and ≥1 sibling | N | N | Rahman, M&F | 1.3 | 0.8 | 0.04 | 0.99 | 3.30 (5 y)

Abbreviations: 1DR=first degree relative; FH=family history; FU=followup; N=no; NPV=negative predictive value; NR=not reported; PPV=positive predictive value; RR=relative risk; y=years

1 RR=relative risk, metric reported unless otherwise stated

2 Male and female data combined

Webtable 17 Predictive values associated with FH definitions for diabetes in cross-sectional analyses

FH category | Specific definition | Age criterion | Lineage criterion | Studies | Disease prevalence in study sample (%) | Prevalence of positive FH in study sample (%) | PPV for study sample | NPV for study sample | Most highly adjusted reported OR or equivalent^1^
B | ≥1 parent | N | N | Nyenwe, M&F | 6.9 | 7.7 | 0.26 | 0.95 | 9.4
B | ≥1 parent | N | N | Annis, M&F | 9.6 | 24.1 | 0.19 | 0.93 | 3.04 (one parent)
B | ≥1 parent | N | N | Carlsson, M&F | 2.1 | 10.4 | 0.05 | 0.98 | 4.62^2^
B | ≥1 parent | N | N | Mohan, M&F | 12.0 | 19.7 | 0.18 | 0.89 | 2.05
B | father | N | N | Annis, M&F | 9.6 | 10.4 | 0.17 | 0.91 | NR
B | father | N | N | Carlsson, M&F | 2.1 | 4.3 | 0.04 | 0.98 | 4.29^2^
B | mother | N | N | Annis, M&F | 9.6 | 16.2 | 0.22 | 0.93 | NR
B | mother | N | N | Carlsson, M&F | 2.1 | 6.6 | 0.06 | 0.98 | 5.17^2^
B | ≥1 sibling | N | N | Annis, M&F | 9.6 | 13.1 | 0.28 | 0.93 | 3.52
B | ≥1 sibling | N | N | Carlsson, M&F | 2.1 | 3.1 | 0.08 | 0.98 | 2.92^2^
B | brother | N | N | Annis, M&F | 9.6 | 7.5 | 0.30 | 0.92 | NR
B | brother | N | N | Carlsson, M&F | 2.1 | 2.5 | 0.10 | 0.98 | 4.76^2^
B | sister | N | N | Annis, M&F | 9.6 | 8.2 | 0.31 | 0.92 | NR
B | sister | N | N | Carlsson, M&F | 2.1 | 2.2 | 0.10 | 0.98 | 4.01^2^
B | ≥1 child | N | N | Carlsson, M&F | 2.1 | 0.8 | 0.06 | 0.98 | 2.40^2^
B | father or brother | N | N | Carlsson, M&F | 2.1 | 5.7 | 0.05 | 0.98 | 3.58^2^
B | mother or sister | N | N | Carlsson, M&F | 2.1 | 7.5 | 0.06 | 0.98 | 4.16^2^
C | ≥1 1DR | N | N | Carlsson, M&F | 2.1 | 15.2 | 0.06 | 0.99 | 3.51^2^
C | ≥1 1DR | N | N | Bindraban, M&F | 13.7 | 59.9 | 0.19 | 0.94 | 2.7
C | ≥1 1DR | N | N | Shera, M | 9.3 | 11.0 | 0.22 | 0.92 | NR
C | ≥1 1DR | N | N | Shera, F | 8.4 | 10.3 | 0.18 | 0.93 | NR
C | ≥1 parent or sibling | N | N | Gikas, M&F | 8.7 | 23.3 | 0.24 | 0.96 | 6.91
C | ≥1 parent or sibling | N | N | Annis, M&F | 9.6 | 31.5 | 0.19 | 0.95 | 3.95
C | ≥1 parent or sibling | N | N | Haron, M | 14.9 | 27.0 | 0.18 | 0.86 | 2.5^3^
C | ≥1 parent or sibling | N | N | Haron, F | 10.6 | 29.9 | 0.14 | 0.91 | 2.5^3^
C | ≥2 1DR | N | N | Carlsson, M&F | 2.1 | 1.9 | 0.13 | 0.98 | 8.33^2^
C | ≥2 1DR (parents or sibling) | N | N | Annis, M&F | 9.6 | 8.2 | 0.32 | 0.92 | 5.14
C | ≥3 1DR (parents or sibling) | N | N | Annis, M&F | 9.6 | 2.2 | 0.52 | 0.91 | 14.83
D | ≥1 1DR, aunt or uncle | N | N | Ebbesson, M&F | 6.2 | 19.0 | 0.12 | 0.95 | 4.4
D | ≥1 1DR, aunt or uncle | N | N | Ebbesson, M | 4.2 | 15.4 | 0.09 | 0.97 | NR
D | ≥1 1DR, aunt or uncle | N | N | Ebbesson, F | 8.8 | 20.0 | 0.17 | 0.93 | NR
D | ≥1 1DR or ≥1 2DR | N | N | Ajlouni, M&F | 17.4 | 43.4 | 0.23 | 0.87 | 3.09
D | ≥1 1DR or ≥2 2DR | N | N | Hilding, M | 2.3 | 50.1 | 0.04 | 0.99 | 3.1
D | ≥1 1DR or ≥2 2DR | N | N | Hilding, F | 1.4 | 52.7 | 0.02 | 0.99 | 1.7
E | ≥1 1DR and 1 2DR, same lineage OR 1 1DR OR both parents OR 2 2DR, same lineage | N | Y | Hariri, M&F | 10.4 | 35.8 | 0.21 | 0.96 | 3.6
E | ≥2 1DR, same lineage OR ≥1 1DR and ≥2 2DR, same lineage OR ≥3 2DR same lineage | N | Y | Hariri, M&F | 10.4 | 16.4 | 0.29 | 0.93 | 4.7

Abbreviations: 1DR=first degree relative; 2DR=second degree relative; FH=family history; N=no; NPV=negative predictive value; NR=not reported; PPV=positive predictive value; RR=relative risk; y=years; Y=yes

1 OR=odds ratio, metric reported unless otherwise stated

2 Type 2 diabetes

3 Data for males and females combined

Webtable 18 Quality items for diabetes studies for review question 1

Author Year | Same outcome ascertainment, irrespective of FH (outcome information bias) | Outcome ascertainment blind to FH (outcome information bias) | Same FH ascertainment, irrespective of disease status (exposure information bias) | FH ascertainment blind to disease status (exposure information bias) | Exclusion of cases at inception (cohort) (misclassification) | Adequate followup (cohort) (selection bias) | Representative sampling (cross-sectional) (selection bias) | Adequate response rate (cross-sectional) (selection bias)
Diabetes
Bjornholt 2000 | Yes | Yes | Yes | Yes | Yes | At least 80% followup | Not applicable (longitudinal design) | Not applicable (longitudinal design)
Mohan 2003 | Yes | No | Unclear | No | Not applicable (cross-sectional design) | Not applicable (cross-sectional design) | Yes (probability sampling) | Yes, response rate at least 80%
Rahman 2008 | Yes | No | Yes | Yes | Yes | At least 80% followup | Not applicable (longitudinal design) | Not applicable (longitudinal design)
Sugimori 1998 | Yes | Yes | Unclear | Yes | Yes | Unclear | Not applicable (longitudinal design) | Not applicable (longitudinal design)
Meigs 2000 | Yes | Unclear | Yes | Yes | Yes | At least 80% followup | Not applicable (longitudinal design) | Not applicable (longitudinal design)
Shera 2006 | Yes | Unclear | Unclear | Unclear | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Yes (probability sampling) | Unclear
Bindraban 2008 | Yes | No | Yes | No | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Yes (probability sampling) | Response rate less than 80%, adequate description of non-participants
Ajlouni 2008 | Yes | No | Unclear | No | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Yes (probability sampling) | Unclear
Boer 1996 | Yes | Unclear | Yes | Yes | Yes | Less than 80% followup, inadequate or missing description of those lost | Not applicable (longitudinal design) | Not applicable (longitudinal design)
Nakanishi 2003 | Yes | Yes | Unclear | Yes | Yes | Unclear | Not applicable (longitudinal design) | Not applicable (longitudinal design)
Hariri 2006 | Yes | No | Yes | No | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Yes (probability sampling) | Response rate less than 80%, inadequate or missing description of non-participants
Haron 2006 | Yes | No | Yes | No | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Yes (probability sampling) | Response rate less than 80%, adequate description of non-participants
Gikas 2004 | Yes | No | Unclear | No | Not applicable (cross sectional design) | Not applicable (cross sectional design) | No (non- probability sampling) | Yes, response rate at least 80%
Hilding 2006 | Yes | Yes | Yes | Yes | Not applicable (cross sectional design) | Not applicable (cross-sectional design) | Unclear | Response rate less than 80%, inadequate or missing description of non
Nyenwe 2003 | Yes | No | Unclear | No | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Yes (probability sampling) | Response rate less than 80%, inadequate or missing description of non
Carlsson 2007 | Unclear | Unclear | Yes | No | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Yes (probability sampling) | Yes, response rate at least 80%
Ebbesson 1998 | Yes | No | Unclear | No | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Yes (probability sampling) | Response rate less than 80%, adequate description of non-participants
Annis 2005 | Yes | No | Yes | No | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Yes (probability sampling) | Unclear
Hariri 2006 | Yes | No | Yes | No | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Yes (probability sampling) | Unclear

Webtable 19 General data for asthma studies

Author Year | Study setting | Study design | n | Sub-groups measured | How/when FH obtained | Definition of outcome | How/when outcome ascertained
Alford 2004 | relationship between parental onset and duration of disease and the risk of paediatric atopic disease in children from birth to 6/7 y old, U.S. | | 835 | childhood and adulthood | maternal interview | asthma: self-report symptoms within previous 12 mo and currently using asthma medication Atopy: positive skin prick test | parental questionnaire plus clinical assessment
Bener 2005 | government primary schools in the State of Qatar | cross-sectional study | 3,204 | school children living in urban and semi-urban areas, 51.9% boys and48.1% girls, with a mean age of 8.92 y | parental interview | ISAAC criteria for self-report of physician diagnosis of asthma OR asthma treatment OR hospital admission | parental questionnaire
Bergmann 1997 | evaluation of parental history and cord blood-IgE for the appropriate atopic phenotypes in the infants in 6 German obstetric department, Germany | cohort | 1,314 | gender, cord blood IgE, family history (father, mother) | parental questionnaire | self-report of physician diagnosis of atopic disease OR diagnosis on basis of research clinical examination or reported symptomatology OR computer algorithm diagnosis on basis of specific criteria for symptomatology and clinical signs | questionnaire, interview, clinical assessment
Chatkin 2003 | children age 4 to5 y in Brazil | cohort | 981 | all subjects | maternal interview | ISAAC criteria for current asthma | parental interview
Chatkin 2005 | male and female children age 6 to7 y in southern Brazil | cross-sectional | 494 | all subjects | maternal interview | ISAAC criteria for current asthma | parental interview
Garcia-Marcos 2005 | evaluation of environmental and family risk factors for atopic and non-atopic wheezing among school children 9–12 y of age (ISAAC phase II), Spain | cross-sectional | 2720 | atopic and non-atopic wheezing | questionnaire | ISAAC criteria for current wheezing | parental questionnaire
Hu 1995 | Los Angeles & San Diego California young adults ages 20 to22 y | cross sectional | 2,041 | all subjects | questionnaire | physician-reported asthma plus one of: asthma medication in previous 12 months or coughing, wheezing, shortness of breath lasting >3 days in previous 12 months | self-report questionnaire
London 2001 | a schoolbased study of Southern California children | cross-sectional | 5,046 | presence of a sibling, maternal smoking | parents or guardians completed a self-administered questionnaire during the school year | “yes” response to the question, has a doctor ever diagnosed this child as having asthma? | parents or guardians completed a self-administered questionnaire during the school year
Lopez 1999 | study of genetic and environmental influences on atopic immune response in term neonates born in women’s health care center, Brazil | cohort | 114 | sex, ethnicity | maternal questionnaire | atopic dermatitis according to criteria of Hanifin & Rajka OR wheezing on at least 2 occasions with good response to beta agonist OR history of immediate urticaria, vomiting, diarrhea and or wheezing in response to specific food at least twice. Single manifestations of symptoms indicating probable disease included | parental questionnaire plus clinical assessment
Melbostad 1998 | Norway, farmers and spouses | cross-sectional | 8,482 | all subjects Never/ever smoker animal production/no animal production | questionnaire | unclear data analyzed for “current asthma’ | self-report questionnaire plus spirometry
Montnemery2000 | study of familial related risk-factors in the development of chronic bronchitis/emphy sema in 20–59 y old population Sweden | cross-sectional | 12073 | age, gender | questionnaire | positive response to question, ‘have you now, or have you had asthma?’ | self-reported
Õneş 1997 | Istanbul, Turkey schoolchildren aged 6 to 12 y | cross-sectional | 2,216 | six randomly selected primary schools | parental questionnaire | ISAAC criteria for self-report of physician diagnosis of asthma | parental questionnaire
Patrzalek 2003 | children age 0 to3 y, Warsaw, Poland | prospective cohort | 141 | all subjects | parental questionnaire | atopic dermatitis OR recurrent wheeze OR food allergy, not further defined | parental questionnaire, clinical assessment, IgE
Pohlabeln 2007 | relationship between pet ownership at time of birth and prevalence of atopic diseases approximately 2 years later in 5 hospitals in three cities. Germany | Cohort | 3,132 | sex, parental education, study center, family history (maternal & paternal, sibling) | maternal questionnaire | ISAAC criteria for atopic disease | parental questionnaire
Sugiyama 2002 | Japanese schoolchildren, 13 to 14 y, part of International Study of Asthma and Allergies in Childhood, Phase One | cross-sectional | 4,466 | all subjects with complete data | questionnaire | ISAAC criteria for mild, moderate or severe wheezing | self-report questionnaire
Tariq 1998 | babies born on the Isle of Wight | prospective cohort | 1,218 | infants at ages 1, 2, and 4 y | interview | asthma:≥3 episodes of wheeze, each lasting ≥3 days; Atopy: ≥3 separate episodes of wheeze, each lasting at least 3 days or recurrent, scaly, pruritic, erythematous rash in typical distribution lasting>6 weeks OR two of thee nasal symptoms (discharge, blockage, recurrent sneezing) accompanied by eye symptoms OR skin rasj or respiratory or abdominal symptoms within 4 hours of ingestion of particular food on 2 occasions | parental report plus skin prick tests

Abbreviations: 1DR=first degree relative; FH=family history; IgE=immunoglobin E; ISAAC=international study of asthma and allergies in childhood; n=number of subjects; y=years; U.S.=United States of America

Webtable 20 Predictive values associated with FH definitions for atopic disease in longitudinal analyses

FH category | Specific definition | Age criterion | Lineage criterion | Studies | Disease prevalence in study sample (%) | Prevalence of positive FH in study sample (%) | PPV for study sample | NPV for study sample | Most highly adjusted reported RR or equivalent^1^ (max length of FU)
B | atopy, both parents | N | N | Bergmann M&F, onset ≤2y | 0.4 | NA | 0.25 | 0.84 | NR
B | atopy, father | N | N | Tariq, M&F, onset ≤4y | 26.8 | 25.5 | 0.29 | 0.74 | NR
B | atopy, father | N | N | Pohlabeln onset ≤2y | 23.0 | 19.8 | 0.27 | 0.78 | NR
B | atopy, mother | N | N | Tariq, M&F onset ≤4y | 26.8 | 33.7 | 0.29 | 0.74 | NR
B | atopy, mother | N | N | Pohlabeln onset ≤2y | 23.0 | 23.4 | 0.29 | 0.79 | NR
B | atopy, ≥1 sibling | N | N | Tariq, M&F, onset ≤4y | 27.3 | 36.9 | 0.34 | 0.76 | 2.2 (4 y)
B | atopy, ≥1 sibling | N | N | Pohlabeln onset ≤2y | 23.0 | 10.6 | 0.33 | 0.78 | NR
C | atopy, ≥1 1DR | N | N | Tariq, M&F, onset ≤4y | 26.8 | 58.5 | 0.29 | 0.77 | 1.6 (4 y)
C | atopy, ≥1 1DR | N | N | Pohlabeln onset ≤2y | 23.0 | 43.1 | 0.28 | 0.81 | NR
D | atopy, ≥1 of parents, siblings, grandparents | N | N | Lopez, onset ≤1y | 38.6 | 53.5 | 0.46 | 0.70 | NR

Abbreviations: 1DR=first degree relative; FH=family history; FU=followup; N=no; NPV=negative predictive value; NR=not reported; PPV=positive predictive value; RR=relative risk; y=years

1 RR=relative risk, metric reported unless otherwise stated

Webtable 21 Predictive values associated with FH definitions for atopic disease cross-sectional analyses

FH category | Specific definition | Age criterion | Lineage criterion | Studies | Disease prevalence in study sample (%) | Prevalence of positive FH in study sample (%) | PPV for study sample | NPV for study sample | Most highly adjusted reported OR or equivalent^1^
B | atopy, ≥1 parent | N | N | Patrzalek, M&F, ≤13y | 36.2 | 22.0 | 0.52 | 0.68 | 11.2
B | atopy, father | N | N | Alford, M&F, onset 6–7y | 30.5 | 37.2 | 0.38 | 0.74 | 1.75
B | atopy, father, childhood | Y | N | Alford, M&F, onset 6–7y | 30.5 | 22.6 | 0.40 | 0.72 | 1.02
B | atopy, mother | N | N | Alford, M&F, onset 6–7y | 30.9 | 45.5 | 0.33 | 0.71 | 1.71
B | atopy, mother, childhood | Y | N | Alford, M&F, onset 6–7y | 30.9 | 25.4 | 0.28 | 0.68 | 0.52

Abbreviations: 1DR=first degree relative; F=female; FH=family history; FU=followup; M=male; N=no; NPV=negative predictive value; OR=odds ratio; PPV=positive predictive value; y=years; Y=yes

1 OR=odds ratio, metric reported unless otherwise stated

Webtable 22 Predictive values associated with FH definitions for asthma in longitudinal analyses

FH category | Specific definition | Age criterion | Lineage criterion | Studies | Disease prevalence in study sample (%) | Prevalence of positive FH in study sample (%) | PPV for study sample | NPV for study sample | Most highly adjusted reported RR or equivalent^1^ (max length of FU)
B | asthma, mother | N | N | Tariq, M&F, onset ≤4y | 14.9 | 10.4 | 0.25 | 0.86 | 3.0 (4 y)
B | atopy, mother | N | N | Tariq, M&F, onset ≤4y | 14.8 | 33.7 | 0.18 | 0.87 | 1.9 (4 y)
C | atopy, ≥1 sibling | N | N | Tariq, M&F, onset ≤4y | 15.9 | 36.9 | 0.21 | 0.87 | 2.2 (4 y)
C | atopy, ≥1 1DR | N | N | Tariq, M&F, onset ≤4y | 14.8 | 58.5 | 0.17 | 0.89 | 2.0

Abbreviations: FH=family history; FU=followup; N=no; NPV=negative predictive value; PPV=positive predictive value; RR=relative risk; y=years

1 RR = relative risk, metric reported unless otherwise stated

Webtable 23 Predictive values associated with FH definitions for asthma in cross-sectional analyses

FH category | Specific definition | Age criterion | Lineage criterion | Studies | Disease prevalence in study sample (%) | Prevalence of positive FH in study sample (%) | PPV for study sample | NPV for study sample | Most highly adjusted reported OR or equivalent^1^
B | asthma, ≥1 parent | N | N | London, M&F, onset 9–16y | 14.4 | 18.8 | 0.30 | 0.89 | NR
B | asthma, father | N | N | London, M&F, onset 9–16y | 14.4 | 8.6 | 0.32 | 0.87 | 4.10 (early) 2.72 (late)
B | asthma, father | N | N | Garcia-Marcos, M&F, onset 9–12y | 13.1 | 5.4 | 0.22 | 0.87 | 1.8 (atopic) 1.6 (non-atopic)
B | asthma, father | N | N | Bener, M&F, onset 6–12y | 19.8 | 9.0 | 0.40 | 0.82 | 2.3
B | asthma, father | N | N | Alford, M&F, onset 6–7y | 6.9 | 8.0 | 0.18 | 0.94 | 6.00
B | asthma, father, childhood | Y | N | Alford, M&F, onset 6–7y | 6.9 | 5.7 | 0.19 | 0.94 | 4.39
B | asthma, mother | N | N | London, M&F, onset 9–16y | 14.4 | 11.3 | 0.29 | 0.87 | 4.06 (early) 2.91 (late)
B | asthma, mother | N | N | Garcia-Marcos, M&F, onset 9–12y | 13.1 | 8.6 | 0.20 | 0.88 | 1.62 (atopic) 1.76 (non-atopic)
B | asthma, mother | N | N | Bener, M&F, onset 6–12y | 19.8 | 11.8 | 0.37 | 0.82 | 2.1
B | asthma, mother | N | N | Alford, M&F, onset 6–7y | 7.1 | 13.6 | 0.08 | 0.93 | 1.06
B | asthma, mother, childhood | Y | N | Alford, M&F, onset 6–7y | 7.1 | 7.8 | 0.08 | 0.93 | -
B | asthma, ≥1 sibling | N | N | Bener, M&F, onset 6–12y | 19.8 | 36.5 | 0.34 | 0.89 | 3.0
B | asthma, both parents | N | N | London, M&F, onset 9–16y | 14.4 | 1.1 | 0.51 | 0.86 | 12.15 (early) 5.38 (late)
B | ≥1 parent or sibling | N | N | Melbostad, M&F | 3.1 | 12.5 | 0.07 | 0.98 | 2.9
C | asthma, ≥1 1DR | N | N | Montnemery, M&F | 5.5 | 17.3 | 0.13 | 0.96 | 3.71
C | asthma, ≥1 1DR | N | N | Hu, M&F, onset ≤20y | 8.2 | 21.9 | 0.17 | 0.94 | 3.3
C | asthma, ≥1 1DR | N | N | Hu, M&F, onset ≤20y | 11.8 | 21.9 | 0.24 | 0.91 | 3.1
C | asthma, ≥1 1DR | N | N | Ones, M&F, onset 6–12y | 9.8 | 7.8 | 0.20 | 0.91 | 2.49
C | asthma, ≥1 1DR | N | N | Chatkin, M&F, onset ≤6y | 12.8 | 51.8 | 0.19 | 0.94 | 2.8
C | asthma, ≥1 1DR | N | N | Chatkin, M&F, onset ≤4y | 18.3 | 56.8 | 0.22 | 0.87 | 1.66
D | asthma, ≥1 1DR or grandparent | N | N | Sugiyama, M&F, onset 13–14y | 7.7 | 19.0 | 0.16 | 0.94 | 2.34 (mild) 4.39 (mod) 3.41 (sev)

Abbreviations: 1DR=first degree relative; F=female; FH=family history; N=no; NPV=negative predictive value; M=male; mod=moderate; NR=not reported; OR=odds ratio; PPV=positive predictive value; sev=severe; y=years; Y=yes

1 OR=odds ratio, metric reported unless otherwise stated

Webtable 24 Quality items for asthma and atopy studies for review question 1

Author Year | Same outcome ascertainment, irrespective of FH (outcome information bias) | Outcome ascertainment blind to FH (outcome information bias) | Same FH ascertainment, irrespective of disease status (exposure information bias) | FH ascertainment blind to disease status (exposure information bias) | Exclusion of cases at inception (cohort) (misclassification) | Adequate followup (cohort) (selection bias) | Representat ive sampling (cross-sectional) (selection bias) | Adequate response rate (cross-sectional) (selection bias)
Asthma & atopy
Tariq 1998 | Yes | No | Yes | Yes | Yes | At least 80% followup | Not applicable (longitudinal design) | Not applicable (longitudinal design)
Hu 1997 | Yes | No | Yes | No | Not applicable (cross sectional design) | Not applicable (cross-sectional design) | Unclear | Response rate less than 80%, inadequate or missing description of non
Melbostad 1998 | Yes | No | Yes | No | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Yes (probability sampling) | Response rate less than 80%, inadequate or missing description of non
Montnemery 2001 | Yes | No | Yes | No | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Yes (probability sampling) | Response rate less than 80%, adequate description of non-participants
London 2001 | Yes | No | Yes | No | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Unclear | Response rate less than 80%, inadequate or missing description of non-participants
Chatkin 2003 | Yes | Unclear | Yes | Unclear | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Yes (probability sampling) | Yes, response rate at least 80%
Chatkin 2005 | Yes | Yes | Yes | No | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Yes (probability sampling) | Yes, response rate at least 80%
Sugiyama 2002 | Yes | No | Yes | No | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Yes (probability sampling) | Response rate less than 80%, adequate description of non-participants
Ones 1997 | Yes | No | Yes | No | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Yes (probability sampling) | Yes, response rate at least 80%
Bener 2005 | Yes | No | Yes | No | Not applicable (cross sectional design) | Not applicable (cross sectional design) | Yes (probability sampling) | Yes, response rate at least 80%
Garcia-Marcos 2005 | Yes | No | Yes | No | Not applicable (cross sectional design) | Not applicable (cross-sectional design) | Yes (probability sampling) | Response rate less than 80%, inadequate or missing description of non-participants
Lopez 1999 | Yes | Unclear | Unclear | Yes | Yes | at least 80% followup | Not applicable (longitudinal design) | Not applicable (longitudinal design)
Pohlabeln 2007 | Yes | Unclear | Yes | Yes | Yes | Less than 80% followup, inadequate or missing description of those lost | Not applicable (longitudinal design) | Not applicable (longitudinal design)
Alford 2004 | Yes | No | Yes | No | Not applicable (cross-sectional design) | Not applicable (cross-sectional design) | Yes (probability sampling) | Response rate less than 80%, inadequate or missing description of non-participants
Bergmann 1997 | Yes | Unclear | Unclear | Yes | Yes | Unclear | Not applicable (longitudinal design) | Not applicable (longitudinal design)
Patrzalek 2003 | Unclear | Unclear | Yes | No | Not applicable (cross-sectional design) | Not applicable (cross-sectional design) | Yes (probability sampling) | Unclear

Webtable 25 General data for mental health studies

Author Year | Study setting | Study design | n | Sub-groups measured | How/when FH obtained | Definition of outcome | How/when outcome ascertained
Reinherz 2003 | predominately Caucasian, working-class community in the north eastern U.S., men and women’s life course of a single age (5–26 y) | prospective cohort | 354 | men and women, age 18 to 26 | participant and maternal survey, methods not clear | DSM-IV criteria for major depression | diagnostic interviews at three time points
Weissman 2005 | 3 – Generation Study U.S. | longitudinal retrospective cohort | 161 | grandchildren of original cohort (generation 3) children of original cohort (generation 2) | clinical assessment of generations one and two of three generation cohort study | best estimate diagnosis, DSM-IV criteria for major depressive disorder, mood disorder | diagnostic interviews

Abbreviations: CIDI=composite international diagnostic interview; DSM III-R=diagnostic and statistical method of mental disorders third edition-revised; DSM IV=diagnostic and statistical method of mental disorders fourth edition; FH=family history; GAS=global assessment scale; MDD=major depressive disorder; n=number of subjects; RCT=randomized controlled study; U.S.=United States of America; y=years

Webtable 26 Predictive values associated with FH definitions for mood disorders in longitudinal analyses

FH category | Specific definition | Age criterion | Lineage criterion | Studies | Disease prevalence in study sample (%) | Prevalence of positive FH in study sample (%) | PPV for study sample | NPV for study sample | Most highly adjusted reported RR or equivalent^1^ (max length of FU)
B | MDD, ≥1 parent | N | N | Weissman, M&F, onset ≤26y | 18.6 | 59.6 | 0.24 | 0.89 | NR
B | MDD, ≥1 grandparent | N | N | Weissman, M&F, onset ≤26y | 18.6 | 62.7 | 0.25 | 0.92 | NR
B | MDD, ≥1 parent and ≥1 grandparent | N | N | Weissman, M&F, onset ≤26y | 18.6 | 44.1 | 0.31 | 0.91 | 2.8

Abbreviations: FH=family history; FU=followup; MDD=major depressive disorder; N=no; NPV=negative predictive value; NR=not reported; PPV=positive predictive value; RR=relative risk; y=years

1 RR=relative risk, metric reported unless otherwise stated

Webtable 27 Predictive values associated with FH definitions for major depressive disorder in longitudinal analyses

FH category | Specific definition | Age criterion | Lineage criterion | Studies | Disease prevalence in study sample (%) | Prevalence of positive FH in study sample (%) | PPV for study sample | NPV for study sample | Most highly adjusted reported RR or equivalent^1^ (max length of FU)
B | | | | Weissman, M&F, onset ≤26y | 11.2 | 59.6 | 0.14 | 0.92 | NR
B | ≥1 grandparent | N | N | Weissman, M&F, onset ≤26y | 11.2 | 62.7 | 0.15 | 0.95 | NR
B | ≥1 parent and ≥1 grandparent | N | N | Weissman, M&F, onset ≤26y | 11.2 | 44.1 | 0.18 | 0.94 | 2.33

Abbreviations: F=female; FH=family history; FU=followup; N=no; NPV=negative predictive value; M=male; NR=not reported; PPV=positive predictive value; RR=relative risk; y=years

1 RR=relative risk, metric reported unless otherwise stated

Webtable 28 Predictive values associated with FH definitions for major depressive disorder in cross-sectional analyses

FH category | Specific definition | Age criterion | Lineage criterion | Studies | Disease prevalence in study sample (%) | Prevalence of positive FH in study sample (%) | PPV for study sample | NPV for study sample | Most highly adjusted reported OR or equivalent^1^
B | ≥1 parent | N | N | Reinherz,M &F, onset ≤26y | 23.2 | 16.9 | 0.33 | 0.79 | 1.84
B | ≥1 sibling | N | N | Reinherz,M &F, onset ≤26y | 23.2 | 6.2 | 0.45 | 0.78 | 2.88

Abbreviations: F=female; FH=family history; N=no; NPV=negative predictive value; M=male; OR=odds ratio; PPV=positive predictive value; y=years

1 OR=odds ratio, metric reported unless otherwise stated

Webtable 29 Quality items for mental illness studies for review question 1

Author Year | Same outcome ascertainment, irrespective of FH (outcome information bias) | Outcome ascertainment blind to FH (outcome information bias) | Same FH ascertainment, irrespective of disease status (exposure information bias) | FH ascertainment blind to disease status (exposure information bias) | Exclusion of cases at inception (cohort) (misclassification) | Adequate followup (cohort) (selection bias) | Representative sampling (cross-sectional) (selection bias) | Adequate response rate (cross-sectional) (selection bias)
Mental illness
Weissman 2005 | Yes | Yes | Yes | Yes | Yes | at least 80% followup | Not applicable (longitudinal design) | Not applicable (longitudinal design)
Reinherz 2003 | Yes | No | Unclear | Unclear | Not applicable (cross-sectional design) | Not applicable (cross-sectional design) | Yes (probability sampling) | Response rate less than 80%, adequate description of non-participants

Webtable 30 Studies excluded from Question 3 and Question 4 because of study design

Studies (stratified by design) | Question exclusion
Case-control
Andersen (2002) | Q4
Bloom (2006) | Q3/Q4
Bottorff (2002) | Q4
Cappelli (2001) | Q4
Cappelli (1999) | Q4
Drossaert (1996) | Q3/Q4
Imperiale (2008) | Q3/Q4
Kaikkonen (2006) | Q3/Q4
Meschia (2006) | Q3/Q4
Perez (2001) | Q4
Tung (2004) | Q3/Q4
Cohort
Calvocoressi (2004) | Q4
Chang (2005) | Q3
Clavel-Chapelon (1999) | Q4
Cobbe (1997) | Q3/Q4
Gil (2003) | Q3/Q4
Phillips (2005) | Q3/Q4
Sellers (1997) | Q3/Q4
Thalib (2004) | Q3/Q4
van Dooren (2005) | Q4
Cross-sectional
Armstrong (2002) | Q3/Q4
Beebe-Dimmer (2004) | Q3/Q4
Bratt (1997) | Q4
Bunn (2002) | Q3/Q4
Cantor (2002) | Q4
Carney (2006) | Q4
Cohen (2006) | Q3/Q4
Costanza (2005) | Q4
Crepeau (2008) | Q4
Criqui (2007) | Q3/Q4
Davids (2004) | Q3/Q4
Dawson (1997) | Q4
Dotterud (1995) | Q3
Drescher (2000) | Q3/Q4
Easton (1996) | Q3/Q4
Erblich (2000) | Q4
Erblich (2000) | Q4
Finney (2001) | Q3/Q4
Fletcher (2007) | Q3/Q4
Friedman (2004) | Q3/Q4
Gaga (2005) | Q3/Q4
Glanz (1999) | Q4
Harpaz (2004) | Q3/Q4
Hebert-Croteau (1997) | Q4
Higgins (2005) | Q3/Q4
Jacobsen (2004) | Q4
Karliner (2007) | Q3/Q4
Laukkanen (2007) | Q3/Q4
Lippert (1999) | Q4
Longacre (2006) | Q4
Lopez-Perez | Q3
MacDonald (2005) | Q4
McCusker (2004) | Q3/Q4
Mellon (2008) | Q4
Murff (2005) | Q3/Q4
Murff (2004) | Q3/Q4
Petersen (1999) | Q3/Q4
Quillin (2006) | Q4
Robb (2004) | Q4
Roncaglioni (2004) | Q4
Rose (1999) | Q3/Q4
Scheuner (2006) | Q3/Q4
Shirakawa (2006) | Q3/Q4
Stark (2006) | Q4
Stoney (1999) | Q4
Tozzi (2008) | Q3/Q4
Van Der Sande (2001) | Q3/Q4
Wang (2006) | Q3
West (2003) | Q3/Q4
Zheng (2006) | Q3/Q4

Webfigure 1 Cancer, risk of bias

Webfigure 2 Mental health disorders, risk of bias

Webfigure 3 Parkinson’s Disease, risk of bias

Webfigure 4 Diabetes, risk of bias

Webfigure 5 Cardiovascular disease and hypertension, risk of bias

## Reference List

Ahn J, Moslehi R, Weinstein SJ, et al. Family history of prostate cancer and prostate cancer risk in the Alpha-Tocopherol, Beta-Carotene Cancer Prevention (ATBC) Study. Int J Cancer. 2008;123(5):1154-9. [pmid: 18546266].
Ajlouni K, Khader YS, Batieha A, et al. An increase in prevalence of diabetes mellitus in Jordan over 10 years. J Diabetes Complications. 2008;22(5):317-24. [pmid: 18413210].
Alford SH, Zoratti E, Peterson EL, et al. Parental history of atopic disease: disease pattern and risk of pediatric atopy in offspring. J Allergy Clin Immunol. 2004;114(5):1046-50. [pmid: 15536408].
Andersen MR, Peacock S, Nelson J, et al. Worry about ovarian cancer risk and use of ovarian cancer screening by women at risk for ovarian cancer. Gynecol Oncol. 2002;85(1):3-8. [pmid: 11925113].
Annis AM, Caulder MS, Cook ML, et al. Family history, diabetes, and other demographic and risk factors among participants of the National Health and Nutrition Examination Survey 1999–2002. Prev Chronic Dis. 2005;2(2):A19. [pmid: 15888230].
Armstrong K, Weber B, Ubel PA, et al. Interest in BRCA1/2 testing in a primary care population. Prev Med. 2002;34(6):590-5. [pmid: 12052018].
Beebe-Dimmer JL, Wood DP Jr, Gruber SB, et al. Risk perception and concern among brothers of men with prostate carcinoma. Cancer. 2004;100(7):1537-44. [pmid: 15042690].
Bener A, Janahi IA, Sabbah A. Genetics and environmental risk factors associated with asthma in schoolchildren. Allerg Immunol (Paris). 2005;37(5):163-8.
Bergmann RL, Edenharter G, Bergmann KE, et al. Predictability of early atopy by cord blood-IgE and parental history. Clin Exp Allergy. 1997;27(7):752-60. [pmid: 9249267].
Bindraban NR, Van Valkengoed IGM, Mairuhu G, et al. Prevalence of diabetes mellitus and the performance of a risk score among Hindustani Surinamese, African Surinamese and ethnic Dutch: A cross-sectional population-based study. BMC Public Health. 2008;8:271. [pmid: 18673544].
Bjornholt JV, Erikssen G, Liestol K, et al. Type 2 diabetes and maternal family history: an impact beyond slow glucose removal rate and fasting hyperglycemia in low-risk individuals? Results from 22.5 years of follow-up of healthy nondiabetic men. Diabetes Care. 2000;23(9):1255-9. [pmid: 10977015].
Bloom JR, Stewart SL, Oakley-Girvans I, et al. Family history, perceived risk, and prostate cancer screening among African American men. Cancer Epidemiol Biomarkers Prev. 2006;15(11):2167-73. [pmid: 17119042].
Boer JM, Feskens EJ, Kromhout D. Characteristics of non-insulin-dependent diabetes mellitus in elderly men: effect modification by family history. Int J Epidemiol. 1996;25(2):394-402. [pmid: 9119566].
Bottorff JL, Ratner PA, Balneaves LG, et al. Women’s interest in genetic testing for breast cancer risk: the influence of sociodemographics and knowledge. Cancer Epidemiol Biomarkers Prev. 2002;11(1):89-95. [pmid: 11815405].
Bratt O, Kristoffersson U, Lundgren R, et al. Sons of men with prostate cancer: Their attitudes regarding possible inheritance of prostate cancer, screening, and genetic testing. Urology. 1997;50(3):360-5. [pmid: 9301698].
Bunn JY, Bosompra K, Ashikaga T, et al. Factors influencing intention to obtain a genetic test for colon cancer risk: A population-based study. Prev Med. 2002;34(6):567-77. [pmid: 12052015].
Byeon J-S, Yang S-K, Kim TI, et al. Colorectal neoplasm in asymptomatic Asians: a prospective multinational multicenter colonoscopy survey. Gastrointest Endosc. 2007;65(7):1015-22. [pmid: 17531636].
Calvocoressi L, Kasl SV, Lee CH, et al. A prospective study of perceived susceptibility to breast cancer and nonadherence to mammography screening guidelines in African American and White women ages 40 to 79 years. Cancer Epidemiol Biomarkers Prev. 2004;13(12):2096-105. [pmid: 15598767].
Cantor SB, Volk RJ, Cass AR, et al. Psychological benefits of prostate cancer screening: The role of reassurance. Health Expect. 2002;5(2):104-13. [pmid: 12031051].
Cappelli M, Surh L, Humphreys L, et al. Psychological and social determinants of women’s decisions to undergo genetic counseling and testing for breast cancer. Clin Genet. 1999;55(6):419-30. [pmid: 10450858].
Cappelli M, Surh L, Walker M, et al. Psychological and social predictors of decisions about genetic testing for breast cancer in high-risk women. Psychol Health Med. 2001;6(3):321-33.
Carlsson S, Midthjell K, Grill V. Influence of family history of diabetes on incidence and prevalence of latent autoimmune diabetes of the adult: results from the Nord-Trondelag Health Study. Diabetes Care. 2007;30(12):3040-5. [pmid: 17878245].
Carney PA, Steiner E, Goodrich ME, et al. Discovery of breast cancers within 1 year of a normal screening mammogram: How are they found?. Ann Fam Med. 2006;4(6):512-8. [pmid: 17148629].
Cauley JA, Song J, Dowsett SA, et al. Risk factors for breast cancer in older women: The relative contribution of bone mineral density and other established risk factors. Breast Cancer Res Treat. 2007;102(2):181-8. [pmid: 17028986].
Cerhan JR, Parker AS, Putnam SD, et al. Family history and prostate cancer risk in a population-based cohort of Iowa men. Cancer Epidemiol Biomarkers Prev. 1999;8(1):53-60. [pmid: 9950240].
Chang WT, Sun HL, Lue KH, et al. Predictability of early onset atopic dermatitis by cord blood IgE and parental history. Acta Paediatrica Taiwanica. 2005;46(5):272-7. [pmid: 16640000].
Chatkin MN, Menezes AMB. Prevalence and risk factors for asthma in schoolchildren in southern Brazil. J Pediatr (Rio J). 2005;81(5):411-6. [pmid: 16247545].
Chatkin MN, Menezes AMB, Victora CG, et al. High prevalence of asthma in preschool children in southern Brazil: A population-based study. Pediatr Pulmonol. 2003;35(4):296-301. [pmid: 12629628].
Chen YC, Page JH, Chen R, et al. Family history of prostate and breast cancer and the risk of prostate cancer in the PSA era. Prostate. 2008;68(14):1582-91. [pmid: 18646000].
Clavel-Chapelon F, Joseph R, Goulard H. Surveillance behavior of women with a reported family history of colorectal cancer. Prev Med. 1999;28(2):174-8. [pmid: 10048109].
Cobbe SM. Baseline risk factors and their association with outcome in the West of Scotland Coronary Prevention Study. Am J Cardiol. 1997;79(6):756-62. [pmid: 9070554].
Cohen M. Breast cancer early detection, health beliefs, and cancer worries in randomly selected women with and without a family history of breast cancer. Psychooncology. 2006;15(10):873-83. [pmid: 16374894].
Costanza ME, Luckmann R, Stoddard AM, et al. Applying a stage model of behavior change to colon cancer screening. Prev Med. 2005;41(3–4):707-19. [pmid: 16171854].
Crepeau AZ, Willoughby L, Pinsky B, et al. Accuracy of personal breast cancer risk estimation in cancer-free women during primary care visits. Women Health. 2008;47(2):113-30. [pmid: 18681103].
Criqui MH, Denenberg JO, Bergan J, et al. Risk factors for chronic venous disease: The San Diego Population Study. J Vasc Surg. 2007;46(2):331-7. [pmid: 17600666].
Davids SL, Schapira MM, McAuliffe TL, et al. Predictors of pessimistic breast cancer risk perceptions in a primary care population. J Gen Intern Med. 2004;19(4):310-5. [pmid: 15061739].
Dawson DA, Grant BF. Family history of alcoholism and gender: Their combined effects on DSM- IV alcohol dependence and major depression. J Stud Alcohol. 1997;59(1):97-106. [pmid: 9498321].
Denic S, Bener A. Consanguinity decreases risk of breast cancer--cervical cancer unaffected. Br J Cancer. 2001;85(11):1675-9. [pmid: 11742487].
Djousse L, Gaziano JM. Parental history of myocardial infarction and risk of heart failure in male physicians. Eur J Clin Invest. 2008;38(12):896-901. [pmid: 19021713].
Dodani S, MacLean DD, LaPorte RE, et al. Distribution and determinants of coronary artery disease in an urban Pakistani setting.[erratum appears in Ethn Dis. 2006 Winter;16(1):309 Note: MacLean, David D [added]; LaPorte, Ronald E [added]; Joffres, Michel [added]]. Ethn Dis. 2005;15(3):429-35. [pmid: 16108303].
Dotterud LK, Kvammen B, Lund E, et al. Prevalence and some clinical aspects of atopic dermatitis in the community of Sor-Varanger. Acta Derm Venereol. 1995;75(1):50-3. [pmid: 7747535].
Drescher C, Holt SK, Andersen MR, et al. Reported ovarian cancer screening among a population-based sample in Washington State. Obstet Gynecol. 2000;96(1):70-4. [pmid: 10862845].
Drossaert CC, Boer H, Seydel ER. Perceived risk, anxiety, mammogram uptake, and breast self-examination of women with a family history of breast cancer: the role of knowing to be at increased risk. Cancer Detect Prev. 1996;20(1):76-85. [pmid: 8907207].
Easton DF, Matthews FE, Ford D, et al. Cancer mortality in relatives of women with ovarian cancer: the OPCS Study. Office of Population Censuses and Surveys. Int J Cancer. 1996;65(3):284-94. [pmid: 8575846].
Ebbesson SOK, Schraer CD, Risica PM, et al. Diabetes and impaired glucose tolerance in three Alaskan Eskimo populations: The Alaska-Siberia project. Diabetes Care. 1998;21(4):563-9. [pmid: 9571343].
Erblich J, Bovbjerg DH, Norman C, et al. It won’t happen to me: lower perception of heart disease risk among women with family histories of breast cancer. Prev Med. 2000;31(6):714-21. [pmid: 11133339].
Erblich J, Bovbjerg DH, Valdimarsdottir HB. Looking forward and back: distress among women at familial risk for breast cancer. Ann Behav Med. 2000;22(1):53-9. [pmid: 10892528].
Finney LJ, Iannotti RJ. The impact of family history of breast cancer on women’s health beliefs, salience of breast cancer family history, and degree of involvement in breast cancer issues. Women Health. 2001;33(3–4):15-28. [pmid: 11527103].
Fletcher RH, Lobb R, Bauer MR, et al. Screening patients with a family history of colorectal cancer. J Gen Intern Med. 2007;22(4):508-13. [pmid: 17372801].
Friedman LC, Webb JA, Everett TE. Psychosocial and medical predictors of colorectal cancer screening among low-income medical outpatients. J Cancer Educ. 2004;19(3):180-6. [pmid: 15458875].
Gaga M, Papageorgiou N, Yiourgioti G, et al. Risk factors and characteristics associated with severe and difficult to treat asthma phenotype: An analysis of the ENFUMOSA group of patients based on the ECRHS questionnaire. Clin Exp Allergy. 2005;35(7):954-9. [pmid: 16008684].
Garcia-Marcos L, Castro-Rodriguez JA, Suarez-Varela MM, et al. A different pattern of risk factors for atopic and non-atopic wheezing in 9–12-year-old children. Pediatr Allergy Immunol. 2005;16(6):471-7. [pmid: 16176393].
Gikas A, Sotiropoulos A, Panagiotakos D, et al. Prevalence, and associated risk factors, of self-reported diabetes mellitus in a sample of adult urban population in Greece: MEDICAL Exit Poll Research in Salamis (MEDICAL EXPRESS 2002). BMC Public Health. 2004;4:1-9. [pmid: 14706119].
Gil F, Mendez I, Sirgo A, et al. Perception of breast cancer risk and surveillance behaviours of women with family history of breast cancer: a brief report on a Spanish cohort. Psychooncology. 2003;12(8):821-7. [pmid: 14681955].
Gillespie J, Wickens K, Siebers R, et al. Endotoxin exposure, wheezing, and rash in infancy in a New Zealand birth cohort. J Allergy Clin Immunol. 2006;118(6):1265-70. [pmid: 17157655].
Glanz K, Grove J, Le Marchand L, et al. Underreporting of family history of colon cancer: correlates and implications. Cancer Epidemiol Biomarkers Prev. 1999;8(7):635-9. [pmid: 10428202].
Granstrom C, Sundquist J, Hemminki K. Population attributable risks for breast cancer in Swedish women by morphological type. Breast Cancer Research & Treatment. 2008;111(3):559-68. [pmid: 17990099].
Halapy E, Chiarelli AM, Klar N, et al. Accuracy of breast screening among women with and without a family history of breast and/or ovarian cancer. Breast Cancer Res Treat. 2005;90(3):299-305. [pmid: 15830144].
Hariri S, Yoon PW, Moonesinghe R, et al. Evaluation of family history as a risk factor and screening tool for detecting undiagnosed diabetes in a nationally representative survey population. Genet Med. 2006;8(12):752-9. [pmid: 17172938].
Hariri S, Yoon PW, Qureshi N, et al. Family history of type 2 diabetes: a population-based screening tool for prevention?. Genet Med. 2006;8(2):102-8. [pmid: 16481893].
Haron Y, Hussein O, Epstein L, et al. Type 2 diabetes among Circassians in Israel. Isr Med Assoc J. 2006;8(9):622-6. [pmid: 17058413].
Harpaz D, Behar S, Rozenman Y, et al. Family history of coronary artery disease and prognosis after first acute myocardial infarction in a national survey. Cardiology. 2004;102(3):140-6. [pmid: 15334023].
Hebert-Croteau N, Goggin P, Kishchuk N. Estimation of breast cancer risk by women aged 40 and over: A population-based study. Can J Public Health. 1997;88(6):392-6. [pmid: 9458566].
Hedlund U, Eriksson K, Ronmark E. Socio-economic status is related to incidence of asthma and respiratory symptoms in adults. Eur Respir J. 2006;28(2):303-10. [pmid: 16540503].
Hennis A, Wu SY, Nemesure B, et al. Diabetes in a Carribean population: Epidemiological profile and implications. Int J Epidemiol. 2002;31(1):234-9. [pmid: 11914326].
Higgins PS, Wakefield D, Cloutier MM. Risk factors for asthma and asthma severity in nonurban children in Connecticut. Chest. 2005;128(6):3846-53. [pmid: 16354853].
Hilding A, Eriksson AK, Agardh EE, et al. The impact of family history of diabetes and lifestyle factors on abnormal glucose regulation in middle-aged Swedish men and women. Diabetologia. 2006;49(11):2589-98. [pmid: 16969647].
Hippe M, Vestbo J, Hein HO, et al. Familial predisposition and susceptibility to the effect of other risk factors for myocardial infarction. J Epidemiol Community Health. 1999;53(5):269-76. [pmid: 10396532].
Hu FB, Persky V, Flay BR, et al. An epidemiological study of asthma prevalence and related factors among young adults. J Asthma. 1997;34(1):67-76. [pmid: 9033442].
Imperiale TF, Kahi CJ, Stuart JS, et al. Risk factors for advanced sporadic colorectal neoplasia in persons younger than age 50. Cancer Detect Prev. 2008;32(1):33-8. [pmid: 18400417].
Jacobsen PB, Lamonde LA, Honour M, et al. Relation of family history of prostate cancer to perceived vulnerability and screening behavior. Psychooncology. 2004;13(2):80-5. [pmid: 14872526].
Jorgensen ME, Bjeregaard P, Borch-Johnsen K, et al. Diabetes and impaired glucose tolerance among the inuit population of greenland. Diabetes Care. 2002;25(10):1766-71. [pmid: 12351475].
Jousilahti P, Puska P, Vartiainen E, et al. Parental history of premature coronary heart disease: an independent risk factor of myocardial infarction. J Clin Epidemiol. 1996;49(5):497-503. [pmid: 8636722].
Jousilahti P, Rastenyte D, Tuomilehto J, et al. Parental history of cardiovascular disease and risk of stroke. A prospective follow-up of 14371 middle-aged men and women in Finland. Stroke. 1997;28(7):1361-6. [pmid: 9227684].
Kadota A, Okamura T, Hozawa A, et al. Relationships between family histories of stroke and of hypertension and stroke mortality: NIPPON DATA80, 1980–1999. Hypertens Res. 2008;31(8):1525-31. [pmid: 18971526].
Kaikkonen KS, Kortelainen ML, Linna E, et al. Family history and the risk of sudden cardiac death as a manifestation of an acute coronary event. Circulation. 2006;114(14):1462-7. [pmid: 17000909].
Kalish LA, McDougal WS, McKinlay JB. Family history and the risk of prostate cancer. Urology. 2000;56(5):803-6. [pmid: 11068306].
Kalyoncu AF, Demir AU, Ozcakar B, et al. Asthma and allergy in Turkish university students: Two cross-sectional surveys 5 years apart. Allergol Immunopathol (Madr). 2001;29(6):264-71. [pmid: 11834185].
Karliner LS, Napoles-Springer A, Kerlikowske K, et al. Missed opportunities: family history and behavioral risk factors in breast cancer risk assessment among a multiethnic group of women. J Gen Intern Med. 2007;22(3):308-14. [pmid: 17356960].
Kerlikowske K, Barclay J, Grady D, et al. Comparison of risk factors for ductal carcinoma in situ and invasive breast cancer. J Natl Cancer Inst. 1997;89(1):76-82. [pmid: 8978410].
Khan S, Roy A, Christopher DJ, et al. Prevalence of bronchial asthma among bank employees of Vellore using questionnaire-based data. J Indian Med Assoc. 2002;100(11):643-4+655. [pmid: 12797634].
Kim CH, Park JY, Lee KU, et al. Fatty liver is an independent risk factor for the development of type 2 diabetes in Korean adults. Diabet Med. 2008;25(4):476-81. [pmid: 18346164].
Krakowiak A, Krawczyk P, Szulc B, et al. Prevalence and host determinants of occupational bronchial asthma in animal shelter workers. Int Arch Occup Environ Health. 2007;80(5):423-32. [pmid: 17021841].
Kulig M, Bergmann R, Edenharter G, et al. Does allergy in parents depend on allergy in their children? Recall bias in parental questioning of atopic diseases. Multicenter Allergy Study Group. J Allergy Clin Immunol. 2000;105(2:Pt 1):274-278. [pmid: 10669847].
Kurukulaaratchy RJ, Fenn M, Matthews S, et al. Characterisation of atopic and non-atopic wheeze in 10 year old children. Thorax. 2004;59(7):563-8. [pmid: 15223861].
Lack G, Fox D, Northstone K, et al. Factors associated with the development of peanut allergy in childhood. N Engl J Med. 2003;348(11):977-85. [pmid: 12637607].
Laukkanen JA, Rauramaa R, Salonen JT, et al. The predictive value of cardiorespiratory fitness combined with coronary risk evaluation and the risk of cardiovascular and all-cause death. J Intern Med. 2007;262(2):263-72. [pmid: 17645594].
Levitt NS, Steyn K, Lambert EV, et al. Modifiable risk factors for Type 2 diabetes mellitus in a peri-urban community in South Africa. Diabet Med. 1999;16(11):946-50. [pmid: 10588525].
Lippert MT, Eaker ED, Vierkant RA, et al. Breast cancer screening and family history among rural women in Wisconsin. Cancer Detect Prev. 1999;23(3):265-72. [pmid: 10337006].
London SJ, James GW, Avol E, et al. Family history and the risk of early-onset persistent, early-onset transient, and late-onset asthma. Epidemiology. 2001;12(5):577-83. [pmid: 11505179].
Longacre AV, Cramer LD, Gross CP. Screening colonoscopy use among individuals at higher colorectal cancer risk. J Clin Gastroenterol. 2006;40(6):490-6. [pmid: 16825930].
Lopez N, Barros-Mazon S, Vilela MM, et al. Genetic and environmental influences on atopic immune response in early life. J Investig Allergol Clin Immunol. 1999;9(6):392-8.
Lopez-Perez G, Morfin-Maciel B, Hernandez T, et al. Prevalence of atopic dermatitis in a group of children in Mexico City. Allergy Clin Immunol Int. 2001;13(6):236-41.
MacDonald DJ, Sarna L, Uman GC, et al. Health beliefs of women with and without breast cancer seeking genetic cancer risk assessment. Cancer Nurs. 380;28(5):372-9.
Magno CP, Araneta MR, Macera CA, et al. Cardiovascular disease prevalence, associated risk factors, and plasma adiponectin levels among Filipino American women.[summary for patients in Ethn Dis. 2008 Autumn;18(4):524; PMID: 19157264]. Ethn Dis. 2008;18(4):458-63. [pmid: 19157250].
Makinen T, Tammela TL, Stenman UH, et al. Family history and prostate cancer screening with prostate-specific antigen. J Clin Oncol. 2002;20(11):2658-63. [pmid: 12039927].
McCusker ME, Yoon PW, Gwinn M, et al. Family history of heart disease and cardiovascular disease risk-reducing behaviors. Genet Med. 2004;6(3):153-8. [pmid: 15354334].
Meigs JB, Cupples LA, Wilson PW. Parental transmission of type 2 diabetes: the Framingham Offspring Study. Diabetes. 2000;49(12):2201-7. [pmid: 11118026].
Melbostad E, Eduard W, Magnus P. Determinants of asthma in a farming population. Scand J Work Environ Health. 1998;24(4):262-9. [pmid: 9754857].
Mellon S, Gold R, Janisse J, et al. Risk perception and cancer worries in families at increased risk of familial breast/ovarian cancer. Psychooncology. 2008;17(8):756-66. [pmid: 18613300].
Meschia JF, Case LD, Worrall BB, et al. Family history of stroke and severity of neurologic deficit after stroke. Neurology. 2006;67(8):1396-402. [pmid: 17060565].
Mohan V, Shanthirani CS, Deepa R. Glucose intolerance (diabetes and IGT) in a selected South Indian population with special reference to family history, obesity and lifestyle factors--the Chennai Urban Population Study (CUPS 14). J Assoc Phys India. 2003;51:771-7.
Montnemery P, Lanke J, Lindholm LH, et al. Familial related risk-factors in the development of chronic bronchitis/emphysema as compared to asthma assessed in a postal survey. Eur J Epidemiol. 2000;16(11):1003-7. [pmid: 11421467].
Morrison AC, Fornage M, Liao D, et al. Parental history of stroke predicts subclinical but not clinical stroke: the Atherosclerosis Risk in Communities Study. Stroke. 2000;31(9):2098-102. [pmid: 10978036].
Motala AA, Esterhuizen T, Gouws E, et al. Diabetes and other disorders of glycemia in a rural South African community: prevalence and associated risk factors. Diabetes Care. 2008;31(9):1783-8. [pmid: 18523142].
Murff HJ, Byrne D, Haas JS, et al. Race and family history assessment for breast cancer. J Gen Intern Med. 2005;20(1):75-80. [pmid: 15693932].
Murff HJ, Byrne D, Syngal S. Cancer risk assessment: quality and impact of the family history interview. Am J Prev Med. 2004;27(3):239-45. [pmid: 15450637].
Nakanishi S, Yamane K, Kamei N, et al. Relationship between development of diabetes and family history by gender in Japanese-Americans. Diabetes Res Clin Pract. 2003;61(2):109-15. [pmid: 12951279].
Nyenwe EA, Odia OJ, Ihekwaba AE, et al. Type 2 diabetes in adult Nigerians: A study of its prevalence and risk factors in Port Harcourt, Nigeria. Diabetes Res Clin Pract. 2003;62(3):177-85. [pmid: 14625132].
Ones U, Sapan N, Somer A, et al. Prevalence of childhood asthma in Istanbul, Turkey. Allergy. 1997;52(5):570-5. [pmid: 9201370].
Ozdemir L, Topcu S, Nadir I, et al. The prevalence of diabetes and impaired glucose tolerance in Sivas, Central Anatolia, Turkey. Diabetes Care. 2005;28(4):795-8. [pmid: 15793175].
Park Y, Lee H, Koh C-S, et al. Prevalence of diabetes and IGT in Yonchon County, South Korea. Diabetes Care. 1995;18(4):545-8. [pmid: 7497867].
Patrzalek M, Najberg E, Piontek E. The effect of chosen environmental factors and family predisposition to atopy in the development of allergic diseases in children. Int Rev Allergol Clin Immunol. 2003;9(4):179-84.
Perez LH, Gutierrez LA, Vioque J, et al. Relation between overweight, diabetes, stress and hypertension: A case-control study in Yarumal - Antioquia, Colombia. Eur J Epidemiol. 2001;17(3):275-80. [pmid: 11680548].
Petersen GM, Larkin E, Codori AM, et al. Attitudes toward colon cancer gene testing: survey of relatives of colon cancer patients. Cancer Epidemiol Biomarkers Prev. 1999;8(4:Pt 2):337-44. [pmid: 10207638].
Phillips KA, Butow PN, Stewart AE, et al. Predictors of participation in clinical and psychosocial follow-up of the kConFab breast cancer family cohort. Fam Cancer. 2005;4(2):105-13. [pmid: 15951960].
Piros S, Karlehagen S, Lappas G, et al. Risk factors for myocardial infarction among Swedish railway engine drivers during 10 years follow-up. J Cardiovasc Risk. 2000;7(5):395-400. [pmid: 11143770].
Pohlabeln H, Jacobs S, Bohmann J. Exposure to pets and the risk of allergic symptoms during the first 2 years of life. J Investig Allergol Clin Immunol. 2007;17(5):302-8.
Quillin JM, Ramakrishnan V, Borzelleca J, et al. Paternal relatives and family history of breast cancer. Am J Prev Med. 2006;31(3):265-8. [pmid: 16905040].
Rahman M, Simmons RK, Harding AH, et al. A simple risk score identifies individuals at high risk of developing type 2 diabetes: A prospective cohort study. Fam Pract. 2008;25(3):191-6. [pmid: 18515811].
Ramachandran A. Epidemiology of diabetes in India--three decades of research. [Review] [25 refs]. J Assoc Phys India. 2005;53:34-8.
Reinherz HZ, Paradis AD, Giaconia RM, et al. Childhood and adolescent predictors of major depression in the transition to adulthood. Am J Psychiatry. 2003;160(12):2141-7. [pmid: 14638584].
Robb KA, Miles A, Wardle J. Demographic and psychosocial factors associated with perceived risk for colorectal cancer. Cancer Epidemiol Biomarkers Prev. 2004;13(3):366-72. [pmid: 15006910].
Rodriguez C, Calle EE, Miracle-McMahill HL, et al. Family history and risk of fatal prostate cancer. Epidemiology. 1997;8(6):653-7. [pmid: 9345665].
Roncaglioni MC, Avanzini F, Roccatagliata D, et al. How general pratitioners perceive and grade the cardiovascular risk of their patients. Eur J Cardiovasc Prev Rehabil. 2004;11(3):233-8. [pmid: 15179106].
Rose P, Humm E, Hey K, et al. Family history taking and genetic counselling in primary care. Fam Pract. 1999;16(1):78-83. [pmid: 10321401].
Sandhu MS, Luben R, Khaw KT. Prevalence and family history of colorectal cancer: implications for screening. J Med Screen. 2001;8(2):69-72. [pmid: 11480446].
Saquib N, Kritz-Silverstein D, Barrett-Connor E. Age at menarche, abnormal glucose tolerance and type 2 diabetes mellitus: The Rancho Bernardo Study. Climacteric. 2005;8(1):76-82. [pmid: 15804735].
Scheuner MT, Whitworth WC, McGruder H, et al. Expanding the definition of a positive family history for early-onset coronary heart disease. Genet Med. 2006;8(8):491-501. [pmid: 16912580].
Sellers TA, Mink PJ, Cerhan JR, et al. The role of hormone replacement therapy in the risk for breast cancer and total mortality in women with a family history of breast cancer. Ann Intern Med. 1997;127(11):973-80. [pmid: 9412302].
Sesso HD, Lee IM, Gaziano JM, et al. Maternal and paternal history of myocardial infarction and risk of cardiovascular disease in men and women. Circulation. 2001;104(4):393-8. [pmid: 11468199].
Shera AS, Jawad F, Maqsood A. Prevalence of diabetes in Pakistan. Diabetes Res Clin Pract. 2007;76(2):219-22. [pmid: 17005289].
Shirakawa T, Ozono R, Kasagi F, et al. Differential impact of family history on age-associated increase in the prevalence of hypertension and diabetes in male Japanese workers. Hypertens Res. 2006;29(2):81-7. [pmid: 16755141].
Stark JR, Bertone-Johnson ER, Costanza ME, et al. Factors associated with colorectal cancer risk perception: the role of polyps and family history. Health Educ Res. 2006;21(5):740-9. [pmid: 16801376].
Stoney CM, Hughes JW. Lipid reactivity among men with a parental history of myocardial infarction. Psychophysiology. 1999;36(4):484-90. [pmid: 10432798].
Sugimori H, Miyakawa M, Yoshida K, et al. Health risk assessment for diabetes mellitus based on longitudinal analysis of MHTS database. J Med Syst. 1998;22(1):27-32. [pmid: 9554107].
Sugiyama T, Sugiyama K, Toda M, et al. Risk factors for asthma and allergic diseases among 13–14-year-old schoolchildren in Japan. Allergol Int. 2002;51(2):139-50.
Tariq SM, Matthews SM, Hakim EA, et al. The prevalence of and risk factors for atopy in early childhood: A whole population birth cohort study. J Allergy Clin Immunol. 1998;101(5):587-93. [pmid: 9600493].
Thalib L, Wedren S, Granath F, et al. Breast cancer prognosis in relation to family history of breast and ovarian cancer. Br J Cancer. 2004;90(7):1378-81. [pmid: 15054458].
Tozzi F, Prokopenko I, Perry JD, et al. Family history of depression is associated with younger age of onset in patients with recurrent depression. Psychol Med. 2008;38(5):641-9. [pmid: 18272011].
Tung KH, Goodman MT, Wu AH, et al. Aggregation of ovarian cancer with breast, ovarian, colorectal, and prostate cancer in first-degree relatives. Am J Epidemiol. 2004;159(8):750-8. [pmid: 15051584].
Van Der Sande MA, Walraven GE, Milligan PJ, et al. Family history: an opportunity for early interventions and improved control of hypertension, obesity and diabetes. Bull World Health Organ. 2001;79(4):321-8. [pmid: 11357211].
van Dooren S, Seynaeve C, Rijnsburger AJ, et al. The impact of having relatives affected with breast cancer on psychological distress in women at increased risk for hereditary breast cancer. Breast Cancer Res Treat. 2005;89(1):75-80. [pmid: 15666200].
Wang IJ, Guo YL, Hwang KC, et al. Genetic and environmental predictors for pediatric atopic dermatitis. Acta Paediatrica Taiwanica. 2006;47(5):238-42. [pmid: 17352311].
Wei EK, Giovannucci E, Wu K, et al. Comparison of risk factors for colon and rectal cancer. Int J Cancer. 2004;108(3):433-42. [pmid: 14648711].
Weissman MM, Wickramaratne P, Nomura Y, et al. Families at high and low risk for depression: a 3-generation study. Arch Gen Psychiatry. 2005;62(1):29-36. [pmid: 15630070].
West DS, Greene PG, Kratt PP, et al. The impact of a family history of breast cancer on screening practices and attitudes in low-income, rural, African American women. J Womens Health (Larchmt). 2003;12(8):779-87. [pmid: 14588128].
Zheng YF, Saito T, Takahashi M, et al. Factors associated with intentions to adhere to colorectal cancer screening follow-up exams. BMC Public Health. 2006;6:272. [pmid: 17083746].