# Forms

Level 1 – Title and Abstract Screening

Level 2 – Title and Abstract Screening

Level 3 – Title and Abstract NQ & BW Screening

Level 4 – Full Text Screening

## Review Question 1: QUALITY ASSESSMENT QUESTIONS

### ALL STUDIES

1. Was the same method of ascertainment of disease outcome applied to all participants, regardless of family history?

a. Yes
b. No
c. Unclear

2. Was ascertainment of disease outcome completely blind to participants’ family history status?

a. Yes
b. No
c. Unclear

3. Was the same method of ascertainment of family history applied to all participants?

a. Yes
b. No
c. Unclear

4. Was ascertainment of family history status completely blind to disease outcome?

a. Yes
b. No
c. Unclear

### LONGITUDINAL DESIGNS ONLY

5. Were participants with the disease outcome excluded at the start of the study?

a. Yes
b. No
c. Unclear
d. Not applicable (cross-sectional design)

6. Was there adequate follow up of all participants?

a. at least 80% follow up
b. Less than 80% follow up, adequate description of those lost
c. Less than 80% follow up, inadequate or missing description of those lost
d. Unclear
e. Not applicable (cross-sectional design)

### CROSS-SECTIONAL DESIGNS ONLY

7. Was the sampling method representative of the population intended to the study?

a. Yes (probability sampling)
b. No (non-probability sampling)
c. Unclear
d. Not applicable (longitudinal design)

8. Was the participation rate adequate?

a. Yes, response rate at least 80%
b. Response rate less than 80%, adequate description of non-participants
c. Response rate less than 80%, inadequate or missing description of non-participants
d. Unclear
e. Not applicable (longitudinal design)

Modified Quality Assessment of Diagnostic Accuracy Studies (OUADAS) 1

QUADAS ITEM (Topic/Bias) | Interpretation for Family History OMAR Review
1) Was the spectrum of patients’ representative of the patients who will receive the test in practice? (Selection) | We are interpreting this to be representative of the spectrum of patients seen within family practice or primary care, which should include all levels of severity or disease duration. The population would be representative of those seen in practice where the test is likely to be applied (primary care settings and providers). Note that this criterion speaks more to generalizability than to a true selection bias. We considered issues of generalisability in terms of a) demographic features (prevalence, age, gender, b) disease characteristics (severity and duration), and c) co-morbidities or differential diagnosis. Note method of recruitment and characteristics of those recruited. YES: Subjects represent spectrum of subjects seen within primary care settings. NO: Not that case control studies are considered by QUADAS to be a NO for this item, but we do not consider this to be a fatal flaw. Subjects that appear to represent a limited portion of the spectrum of patients with respect to disease severity, or duration, or risk for positive family history. Our review did not exclude studies that included subjects from specialty clinics or relatives of persons with the disease. As such, these relative may also be considered to be “high risk” for the disease (as the subjects patients may appear to be recruited because of high risk for family history and are scored NO. UNCLEAR: Description of participants is partial and there is uncertainty of the severity or duration of the disease.
2) Were the selection criteria clearly described? (Selection) | Look for a clear definition of the eligibility criteria (both inclusion and EXCLUSION criteria). Note the criteria used to select BOTH the proband/control and the relatives/informants. YES: Appears that sufficient description of the [underlined: eligibility criteria], the [underlined: process of recruiting] for both the probands/informants and the relatives. NO: All relevant information for selection processes is not reported. The following information may be omitted or poorly described:; a. how the probands/informants were selected (possibly how the proxy informants were selected); b. how the relatives were selected; UNCLEAR: Only partial information is reported and don’t feel you have enough information to score this item.
3) Is the reference standard likely to correctly classify the target intervention? (Misclassification) | The reference standard is the method used to determine the presence or absence of the target condition. The reference standard is therefore an important determinant of the diagnostic accuracy of a test. Estimates of test performance are based on the assumption that the index test is being compared to a reference standard which is 100% sensitive and specific. Not applicable to this systematic review as we limited this review to including studies that used methods of the reference standard that we consider to correctly classify the target condition.
4) Is the reference standard and index test short enough to be reasonably sure the target condition did not change between the two tests? (Misclassification) | This problem may lead to misclassification bias as the disease may progress to a more advanced stage or there may be spontaneous recover. We do not anticipate that this is the context for family history, whereby the interval within which testing occurs will cause family history to be altered. Not applicable to this systematic review.
5) Did the whole sample or a random selection of the sample receive verification using a reference standard of diagnosis? (Partial Verification bias) | This item concerns to partial verification bias which occurs when not all of the study participants receive the reference standard (in our context, confirmation of the TRUE disease status). This is a form of selection bias. Sometimes the reason only a part of the sample receives the reference standard is because knowledge of the index test results influence the decision to perform the reference standard. Please note that in the context of family history, the reference standard can only be applied to the family members or relatives. The probands or informants are in essence the “index test” even though we are interested in the accuracy of the probands/informants. We consider the whole sample to be ALL relatives for which the proband or informant provided information (including “Don’t know” status). YES: All relatives that the proband identifies/reports upon represent the whole sample of relatives. As such, some form of verification is attempted for all identified relatives. NO: Not all relatives receive verification via the reference standard. As such, we consider partial verification bias to be present in the following situations:; 1. Knowledge of the index test will determine which relatives are reported to have the disease status. Often UNAFFECTED relatives do not have their disease status verified by any method (assume proband/informant report is the truth of the disease status); in this case, the disease status is verified in the AFFECTED relatives only. In this situation the outcomes of sensitivity and specificity cannot be computed.; 2. Relatives for which the proband/informant indicates “Don’t know status” are excluded and do not have their disease status verified (no reference standard testing).; 3. Relatives that are DECEASED; as such they are excluded from having any verification undertaken (no reference standard testing).; 4. Relatives that are UNABLE TO PARTICIPATE in interviews or further clinical testing are excluded from having any verification method (no reference standard testing).; UNCLEAR: Insufficient information to determine whether partial verification was present.
6) Did the patients receive the same reference standard regardless of the index test? (Differential Verification Bias) | “Differential verification bias occurs when some of the index test results are verified by a [underlined: different] reference standard. This is especially a problem if multimodal types of reference standards are used. For example, differential verification bias usually occurs when relatives who are testing positive (have the disease) based on the proband report “index test receive” a more invasive or extensive reference standard than those with a negative test result. In most accuracy studies evaluating the reporting of family history, there is the use of more than one method to verify the disease status of the relative and we have restricted these to interview with relative, medical record, disease or death registry, and contact with the subject physician. Using multi-modal approaches to verification of disease status seems to be necessary for this area of research; relatives may be deceased, live afar, or are incapacitated because of disease or frailty. It is expected that most studies will be unable to use a single reference standard method (for example interview with the relative) for all identified relatives. Verification can occur by different methods for different relatives or verification using multiple methods on the SAME relative (and a hierarchy of selection for disease status is used) [See Elbaz 2003^2^ In the latter case, some authors state decision rules at which of the multiple tests will be considered to reflect the truth of the disease status of the relative. In the area of mental health disorders, they will often consider “multiple informants” as the “reference” standard” and only include relatives for which there were “verification” reports from more than one informant. YES: All relatives received the SAME reference standard (for example, all living relatives were interviewed, and all deceased relatives had a proxy informant (for example interview with a spouse of the deceased relative). NO: All relatives did NOT receive the same references standard:; 1. This item can indicate that some of the relatives received a DIFFERENT reference standard. For example, consider the case where:; a. UNAFFECTED relatives have their disease status checked with medical records alone rather than interview or disease or death registry; b. POSITIVE SCREEN relatives get a physical examination but those screening negative do NOT get a physical examination.; c. DECEASED relatives have their disease status checked through medical records or interviews of other relatives (rather than neurological exam received by living relatives).; d. From all informants/relatives who were identified and provided some initial information, only those available for direct interview are provided with more extensive testing (for example with diagnostic mental health instruments); these relatives/informants receive more extensive evaluation (i.e. different and additional reference standard tests).; UNCLEAR: Some information provided but insufficient to determine this item.
7) Was the reference standard independent of the index test (i.e. the index test did not form part of the reference standard)? (Incorporation bias) | “When the result of the index test is used in establishing the final diagnosis, incorporation bias may occur. This incorporation will probably increase the amount of agreement between index test results and the outcome of the reference standard, and hence overestimate the various measures of diagnostic accuracy.” This item is not applicable in tests that do not use multiple tests as part of the reference standards. The index test in this systematic review is the reporting of family history by the probands or informants. There are some special situations where informants are unable to provide family history information (for example they are too ill); in these situations, proxy family members are asked to provide the family history. These same family members, who served as proxy informants, may also be asked about their own disease status and may have knowledge of the responses they gave on behalf of the informant. We view this as an issue of masking bias, not incorporation bias. In the mental health area, family history is often included as part of a list of criteria to determine the disease status of either the proband OR the relative. In addition to inquiring about family history, the verification of the disease is established by asking probands or relatives a checklist of symptoms or other questions related to establishing diagnostic criteria. Thus, in this situation, there is the potential for incorporation bias, as the knowledge of the family history OR details of the presence or absence of symptoms (provided by the informant or proband) may be used to establish the mental health disorder within the relative. In some studies evaluating probands with mental health disorders, the authors make it very clear that different instruments were used to collect family history from the probands and from the relatives. In this case, although family history is collected from both the proband/informant and the relative, we are assuming this is NOT incorporation bias. The response of the proband/informant is independent and is not included in the information collected to establish disease within the relative. YES: The index test (proband/informant) reporting of family history is NOT included in the determination of the disease status of the relatives. NO: The index test (proband/informant) reporting of family history is included in the determination of the disease status of the relatives. UNCLEAR: Some information provided but insufficient to determine this item.
8) Was the execution of the index test described in sufficient detail to permit replication of the test? (Incorporation bias) | We are looking for sufficient detail for REPLICATION of the index test. This should include details of the “questions” used to probe family history, and if possible the degree of relative (for example 1DR, 2DR, etc). Additionally, in studies evaluating probands with mental health disorders, note the sequence when family history was collected. We fully anticipate that there will be differences in the ways in which family history is collected across studies. If reported, evaluate the manner in which “don’t know” information was captured and classified. NB: We are aware that even if the method is replicable, it may not capture the quality of the manner in which FHx was captured; that is the study describes in detail the question used to probe family history, but the question is not well structured and may lead to poor or erroneous responses from the proband/informant. In this case, although the method was “replicable”, we do not evaluate this as NO for QUADAS; rather we comment on the nature of the question. YES: If the manner in which FHx was collected is well specified (for example, standardized questions, or instrument are detailed). NO: There is no information about the manner in which FHx was probed (for example the questions asked) or the methods used to collect the information (not clear if a standardized format was used). UNCLEAR: Indicate that a standardized instrument was used, but do not know what was probed. Partial information is provided but not enough to score this item.
9) Was the execution of the reference standard described in sufficient detail to permit its replication? (Incorporation bias) | In the case of the reference standard, we are looking for sufficient detail to be able to REPLICATE how disease status was established. In the case where interview of the relative is used as a reference standard, any additional probing (for example questions to establish presence of mental health disorder) should also be described. Note that in most studies multi-modal approaches were used to establish the disease status of the relative. As such it is important that the authors describe how 1) deceased versus living relatives had their disease status verified, 2) positive versus negative status relatives (based on index test) had their disease status verified, 3) relatives that were unable to be contacted or participate, and 4) relatives for which no additional information could be obtained. If reported evaluate how “don’t know” information was captured and classified. YES: Indicate the manner in which the disease status was established in relatives (self report, medical chart, linkage with registry, physical examination, etc). Note how missing information or “don’t know” (due to inability to get records for example) are handled. NO: The information is insufficient to replicate the reference standard. UNCLEAR: Indicate methods for some of the multiple sources used to verify the disease status within relatives but insufficient information to score this item.
10) Were the index test results interpreted without knowledge of the results of the reference standard? (Blinding) | We assume this bias to be associated with the collection of data from the researchers and is related to “review bias” or blinding. Family history collection from probands/informants generally precedes contact with relatives for subsequent verification. As such the data collectors would typically not be aware of the true disease status of the relative when collecting family history from the informant. However, for some diseases, proxy informants (often relatives) are used when informants are incapacitated or deceased). In the context of this systematic review, bias can occur when the proxy members used to provide family history are also the relatives who are used to verify their own or others disease status. They are not blind to their previous report of the disease status of their own health or that of other relatives. YES: Index test results were interpreted without knowledge of the relatives’ disease status. If proxy informants (i.e. relatives) had their disease status verified by means other than interview (for example medical record linkage or clinical assessment), OR the proxy informants who are relatives were excluded from the pool of relatives in the analysis, then score YES for this item. NO: Index test are not interpreted without knowledge of the reference standard. Also, the potential for masking bias is likely, when the proxy informants (i.e. relatives) were used and then these SAME relatives were then asked to confirm their own or other relatives disease status by interview only. UNCLEAR: Partial description is provided but not enough information to score this item.
11) Were the reference standard results interpreted without knowledge of the index test? (Blinding) | We assume this bias to be associated with the collection of data from the researchers and is related to “review bias” or blinding. Contact with the relatives is dependent on some minimal information or screening provided by the proband/informant. However, there is the possibility that the data collectors who contact the relatives (or check their medical records, etc.) are not blind to the report given by the proband/informant. Specifically, we look for a description specifying the masking of the data collectors of the reference standard. In the mental health area, data collectors ask relatives a series of screening questions to determine the presence of a mental health disorder. Subsequently, their responses to these questions are used by an EXTERNAL diagnostician to determine the status of the disease. Although, in some cases it is not clear if the data collector was blind to the report from the index test (proband/informant report), we do accept the external diagnostician as being blind in this case. YES: Study reports or methods describe blinding of data collectors or diagnostician verifying the disease status of the relative. NO: Study reports or methods confirm lack of blinding of the data collector to their disease status base don the informant report of family history. UNCLEAR: Blinding for some of the verification methods but not all of the methods is provided or there insufficient information to judge this item.
12) Were the same clinical data available when test results were interpreted as would be available when the test is used in practice? (Misclassification) | QUADAS instructions suggest that if the interpretation of the index test is fully automated and involves no interpretation then this item may not be relevant and can be omitted from the quality assessment tool. However, the interpretation of the family history collection (index test) may require some judgement and depends on what is asked of the proband/informant or relative. Clinical data in the context of family history collection in primary care, could refer to information from direct observation, or access to proxy informants (such as a 1DR who may accompany the proband). It is unlikely that a primary care physician may have access to medical records, disease registries and death registries with information about the status of the relatives. In the context of this systematic review, this item will not discriminate between studies; we will omit this item.
13) Were un-interpretable/intermediate test results reported? (Misclassification) | In the context of family history collection it was difficult to define what results were “uninterpretable”. We assume that this item is interpreted to apply to disease status classification when the proband/informant (index test) did not know the disease status of the relative. Similarly, the disease status of the relative (reference standard) is not known or cannot be confirmed (for example, medical records may not have been easily obtained, or were inconclusive with regards to the disease status, or self report was unclear). In many studies (particularly mental health disorders) many of the relatives were excluded from the analysis and as such this is an issue of partial verification or a case of differential verification. In the context of this systematic review this item could not be disentangled from partial and differential verification bias and was not applicabled
14) Were withdrawals for the study explained? (Misclassification) | “This occurs when subjects withdraw from the study before the results of either the index test or reference standard test are known. Note that the subjects considered in the context of the review include both the proband/informant sample AND the relatives/proxy sample. If patients differ systematically from those that remain in the analysis, then there is the potential for bias. We consider the sample of relatives to be those reported from the probands/informants during the index test. As such, some studies do not specify the total sample of relatives reported; rather they report the number of relatives/informants for which data was available. Potential subjects recruited can include those that are 1) alive, 2) deceased and a best proxy is found, 3) incapacitated to be interviewed and a best proxy is found, Potential recruited subjects are likely to be excluded if 1) they refuse to participate, or b) a proxy informant is not found. In some studies, subjects were further excluded if there was not a match 9 YES: If all probands/informants are accounted for in a flow diagram or reporting details; this includes the number of subjects as follows:; 1. those recruited; 2. providing consent or refusing consent; 3. for which a proxy respondent could not be provided; 4. unable to complete the family history collection (for example due to frailty); 5. number not able to contact; If all relatives (identified by the proband/informants/ or registry) are accounted for in a flow diagram or reporting details; this includes the number of subjects as follows:; 1. ALL relatives identified by the probands/informants/registry; 2. relatives who gave consent or those refusing consent; 3. unable to complete family history; 4. for which a proxy informant could not be found; 5. who were deceased; 6. could not be contacted; 7. unable to get verification of disease status; NO: If all informants who entered the study are not accounted for. UNCLEAR: Partial information is provided, but insufficient to judge this criteria.

Modified QUADAS form

REF ID# | AUTHOR/YEAR
QUADAS ITEM | RESPONSE | COMMENTS
1) Was the spectrum of patients’ representative of the patients who will receive the test in practice? | YES NO UNCLEAR
2) Were the selection criteria clearly described? | YES NO UNCLEAR
3) Is the reference standard likely to correctly classify the target intervention? | YES NO UNCLEAR
4) Is the reference standard and index test short enough to be reasonably sure the target condition did not change between the two tests? | YES NO UNCLEAR
5) Did the whole sample or a random selection of the sample receive verification using a reference standard of diagnosis? | YES NO UNCLEAR
6) Did the patients receive the same reference standard regardless of the index test? | YES NO UNCLEAR
7) Was the reference standard independent of the index test (i.e. the index test did not form part of the reference standard)? | YES NO UNCLEAR
8) Was the execution of the index test described in sufficient detail to permit replication of the test? | YES NO UNCLEAR
9. Was the execution of the reference standard described in sufficient detail to permit its replication? | YES NO UNCLEAR
10) Were the index test results interpreted without knowledge of the results of the reference standard? | YES NO UNCLEAR
11) Were the reference standard results interpreted without knowledge of the index test? | YES NO UNCLEAR
12) Were the same clinical data available when test results were interpreted as would be available when the test is used in practice? | YES NO UNCLEAR
13) Were uninterpretable/intermediate test results reported? | YES NO UNCLEAR
14) Were withdrawals for the study explained? | YES NO UNCLEAR

#### References

Elbaz A, McDonnell SK, Maraganore DM, et al. Validity of family history data on PD: evidence for a family information bias. Neurology. 2003;61(1):11-7.
Whiting PF, Weswood ME, Rutjes AW, et al. Evaluation of QUADAS, a tool for the quality assessment of diagnostic accuracy studies. BMC Med Res Methodol. 2006;6:9. [pmid: 16519814].