# Search Strategies Detailed

## Main Review

### Medline

1. Ambulatory care/
2. ambulatory care.tw.
3. Primary health care/
4. Physicians, family/
5. Family practice/
6. primary health care.tw.
7. primary healthcare.tw.
8. primary care.tw.
9. general practi*.tw.
10. family practic*.tw.
11. (family adj2 (physician? or doctor? or clinic?)).tw.
12. family medical care.tw.
13. gp.ti,ab.
14. Community health services/
15. or/1–14
16. exp Pedigree/
17. limit 16 to humans
18. Medical History Taking/
19. Genetic Predisposition to Disease/
20. anamnesis.ti,ab.
21. ((family or familial) adj3 (histor$ or history-taking or risk$)).ti.
22. (human adj2 pedigree).ti,ab.
23. Family Health/
24. (family history adj3 (taking or collect$ or tool? or questionnaire? or form? or algorith?m or assessment)).ti,ab.
25. (familial history adj3 (taking or collect$ or tool? or questionnaire? or form? or algorith?m or assessment)).ti,ab.
26. (genetic adj2 (risk adj3 (assessment or evaluation))).ti,ab.
27. ((first or second) adj2 degree relative?).ti,ab.
28. ((parental or paternal or maternal) adj2 history).ti.
29. or/17–28
30. (sensitivity or specificity).ti.
31. (accura$ or inaccur$ or valid$ or reliability).ti.
32. under reporting.ti.
33. underreporting.ti.
34. exp “Reproducibility of Results”/
35. completeness.ti.
36. consistency.ti.
37. or/30–36
38. Risk factors.ti.
39. *risk factors/
40. or/38–39
41. family history.tw.
42. 41 and 40
43. exp Stroke/ge, ep, pc, et [Genetics, Epidemiology, Prevention & Control, Etiology]
44. (stroke$ or cerebrovascular$ or cerebral vascular or CVA$).ti.
45. ((cerebral or cerebellar or brainstem or vertebrobasilar) adj5 (infarct$ or isch?emi$ or thrombo$ or apoplexy or emboli$)).ti.
46. ((cerebral or intracerebral or intracranial or parenchymal or brain or intraventricular or brainstem or cerebellar or infratentorial or supratentorial or subarachnoid) adj (haemorrhage or hemorrhage or haematoma or hematoma or bleeding or aneurysm)).ti.
47. or/43–46
48. Asthma/ge, pc, et, ep [Genetics, Prevention & Control, Etiology, Epidemiology]
49. (asthma or atopy or atopic).ti.
50. or/48–49
51. Depression/pc, ep, ge, et [Prevention & Control, Epidemiology, Genetics, Etiology]
52. Depressive Disorder, Major/pc, ep, et, ge [Prevention & Control, Epidemiology, Etiology, Genetics]
53. (involutional adj2 (depress$ or psychos$ or melancholia)).ti.
54. ((major or chronic) adj2 depress$).ti.
55. or/51–54
56. exp Diabetes Mellitus, Type 1/ge, ep, pc, et [Genetics, Epidemiology, Prevention & Control, Etiology]
57. Diabetes Mellitus/et, pc, ge, ep [Etiology, Prevention & Control, Genetics, Epidemiology]
58. exp Diabetes Mellitus, Type 2/ge, ep, pc, et [Genetics, Epidemiology, Prevention & Control, Etiology]
59. (diabetes or diabetic?).ti.
60. or/56–59
61. ((breast or ovar$ or prostate or colon or colorectal or lung) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti.
62. exp Breast Neoplasms/et, ge, ep, pc [Etiology, Genetics, Epidemiology, Prevention & Control]
63. exp Colorectal Neoplasms/ge, pc, et, ep [Genetics, Prevention & Control, Etiology, Epidemiology]
64. exp Ovarian Neoplasms/et, ge, ep, pc [Etiology, Genetics, Epidemiology, Prevention & Control]
65. exp Prostatic Neoplasms/et, ge, ep, pc [Etiology, Genetics, Epidemiology, Prevention & Control]
66. exp Lung Neoplasms/et, ge, ep, pc [Etiology, Genetics, Epidemiology, Prevention & Control]
67. or/61–66
68. exp Cardiovascular Diseases/pc, ge, ep, et [Prevention & Control, Genetics, Epidemiology, Etiology]
69. chd.ti.
70. thrombo$.ti.
71. ((coronary or heart or cardiovascular) adj2 disease?).ti.
72. or/68–71
73. 60 or 55 or 72 or 50 or 67 or 47
74. 15 or 37 or 73
75. 74 and 29
76. 75 or 42
77. (note or comment or editorial or letter or congresses).pt.
78. 76 not 77
79. animals/ not (humans/ and animals/)
80. 78 not 79
81. limit 80 to english language
82. limit 81 to yr=“1995 – 2008”

### EMBASE

1. general practice/ or primary medical care/ or private practice/
2. exp ambulatory care/ or exp primary health care/
3. general practitioner/
4. exp community care/
5. ambulatory care.tw.
6. primary health care.tw.
7. primary healthcare.tw.
8. general practi*.tw.
9. family practi*.tw.
10. primary care.tw.
11. (family adj2 (physician? or doctor? or clinic?)).tw.
12. family medical care.tw.
13. gp.ti,ab.
14. or/1–13
15. “sensitivity and specificity”/
16. exp Validity/
17. exp Reproducibility/
18. (sensitivity or specificity).ti.
19. (accura$ or inaccur$ or valid$ or reliability).ti.
20. under reporting.ti.
21. underreporting.ti.
22. consistency.ti.
23. completeness.ti.
24. or/15–23
25. family history/
26. ((family or familial) adj3 (histor$ or history-taking or risk$)).ti.
27. (human adj2 pedigree).ti,ab.
28. (family history adj3 (taking or collect$ or tool? or questionnaire? or form? or algorith?m or assessment)).ti,ab.
29. (genetic adj2 (risk adj3 (assessment or evaluation))).ti,ab.
30. ((first or second) adj2 degree relative?).ti,ab.
31. ((parental or paternal or maternal) adj2 history).ti.
32. or/25–31
33. *risk factor/
34. risk factor?.ti.
35. or/33–34
36. family history/
37. family history.tw.
38. or/36–37
39. 38 and 35
40. exp Asthma/
41. (asthma* or atopy or atopic).ti.
42. Atopy/
43. or/40–42
44. endogenous depression/ or involutional depression/ or major depression/
45. (involutional adj2 (depress$ or psychos$ or melancholia)).ti.
46. ((major or chronic) adj2 depress$).ti.
47. or/44–46
48. exp Diabetes Mellitus/
49. (diabetes or diabetic?).ti.
50. or/48–49
51. exp Breast Cancer/
52. exp Ovary Cancer/
53. exp Prostate Cancer/
54. exp Colorectal Cancer/
55. exp Lung Cancer/
56. ((breast or ovar$ or prostate or colon or colorectal or lung) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti.
57. or/51–56
58. exp cardiovascular disease/
59. chd.ti.
60. thrombo$.ti.
61. ((coronary or heart or cardiovascular) adj2 disease?).ti.
62. (stroke$ or cerebrovascular$ or cerebral vascular or CVA$).ti.
63. ((cerebral or cerebellar or brainstem or vertebrobasilar) adj5 (infarct$ or isch?emi$ or thrombo$ or apoplexy or emboli$)).ti.
64. ((cerebral or intracerebral or intracranial or parenchymal or brain or intraventricular or brainstem or cerebellar or infratentorial or supratentorial or subarachnoid) adj (haemorrhage or hemorrhage or haematoma or hematoma or bleeding or aneurysm)).ti.
65. or/58–64
66. 57 or 47 or 65 or 50 or 43
67. 24 or 14 or 66
68. 67 and 32
69. 68 or 39
70. limit 69 to human
71. limit 70 to english language
72. (conference paper or editorial or letter or note or proceeding).pt.
73. 71 not 72
74. limit 73 to yr=“1995 – 2008”

### CINAHL

1. Primary Health Care/
2. primary health care.tw.
3. primary healthcare.tw.
4. primary care.tw.
5. Physicians, Family/
6. Family Practice/
7. general practi*.tw.
8. family practic*.tw.
9. (family adj2 (physician? or doctor? or clinic?)).tw.
10. family medical care.tw.
11. gp.ti,ab.
12. (family adj2 (medic* or care)).tw.
13. Community Health Services/
14. or/1–13
15. exp “Reliability and Validity”/
16. “Reproducibility of Results”/
17. (sensitivity or specificity).ti.
18. (accura$ or inaccur$ or valid$ or reliability).ti.
19. under reporting.ti.
20. underreporting.ti.
21. consistency.ti.
22. completeness.ti.
23. or/15–22
24. family history/
25. ((family or familial) adj3 (histor$ or history-taking or risk$)).ti.
26. (human adj2 pedigree).ti,ab.
27. (family history adj3 (taking or collect$ or tool? or questionnaire? or form? or algorith?m or assessment)).ti,ab.
28. (genetic adj2 (risk adj3 (assessment or evaluation))).ti,ab.
29. ((first or second) adj2 degree relative?).ti,ab.
30. ((parental or paternal or maternal) adj2 history).ti.
31. or/24–30
32. Stroke/
33. (stroke$ or cerebrovascular$ or cerebral vascular or CVA$).ti.
34. ((cerebral or cerebellar or brainstem or vertebrobasilar) adj5 (infarct$ or isch?emi$ or thrombo$ or apoplexy or emboli$)).ti.
35. ((cerebral or intracerebral or intracranial or parenchymal or brain or intraventricular or brainstem or cerebellar or infratentorial or supratentorial or subarachnoid) adj (haemorrhage or hemorrhage or haematoma or hematoma or bleeding or aneurysm)).ti.
36. or/32–35
37. Asthma/
38. (asthma* or atopy or atopic).ti.
39. or/37–38
40. Depression/
41. (involutional adj2 (depress$ or psychos$ or melancholia)).ti.
42. ((major or chronic) adj2 depress$).ti.
43. or/40–42
44. diabetes mellitus/ or diabetes mellitus, insulin-dependent/ or diabetes mellitus, non-insulin-dependent/
45. (diabetes or diabetic?).ti.
46. or/44–45
47. exp Breast Neoplasms/
48. exp Colorectal Neoplasms/
49. exp Ovarian Neoplasms/
50. exp Prostatic Neoplasms/
51. exp Lung Neoplasms/
52. ((breast or ovar$ or prostate or colon or colorectal or lung) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti.
53. or/47–52
54. exp Cardiovascular Diseases/
55. chd.ti.
56. thrombo$.ti.
57. ((coronary or heart or cardiovascular) adj2 disease?).ti.
58. or/54–57
59. 46 or 43 or 36 or 39 or 53 or 58
60. 14 or 59 or 23
61. 60 and 31
62. limit 61 to english language
63. limit 62 to (abstract or “book review” or commentary or doctoral dissertation or editorial or exam questions or letter or masters thesis or pamphlet)
64. 62 not 63
65. limit 64 to yr=“1995 – 2008”

### psycINFO

1. cerebrovascular accidents/
2. (stroke$ or cerebrovascular$ or cerebral vascular or CVA$).ti.
3. ((cerebral or cerebellar or brainstem or vertebrobasilar) adj5 (infarct$ or isch?emi$ or thrombo$ or apoplexy or emboli$)).ti.
4. ((cerebral or intracerebral or intracranial or parenchymal or brain or intraventricular or brainstem or cerebellar or infratentorial or supratentorial or subarachnoid) adj (haemorrhage or hemorrhage or haematoma or hematoma or bleeding or aneurysm)).ti.
5. or/1–4
6. asthma/
7. asthma.ti.
8. exp major depression/
9. (involutional adj2 (depress$ or psychos$ or melancholia)).ti.
10. ((major or chronic or severe) adj2 depress$).ti.
11. or/8–10
12. diabetes mellitus/
13. (diabetes or diabetic?).ti.
14. or/12–13
15. exp Ovaries/
16. exp Colon Disorders/
17. exp Prostate/
18. lung disorders/
19. or/15–18
20. exp Neoplasms/
21. cancer.ti.
22. or/20–21
23. 22 and 19
24. Breast Neoplasms/
25. ((breast or ovar$ or prostate or colon or colorectal or lung) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti.
26. or/23–25
27. exp cardiovascular disorders/
28. chd.ti.
29. thrombo$.ti.
30. ((coronary or heart or cardiovascular) adj2 disease?).ti.
31. or/27–30
32. 11 or 26 or 31 or 14 or 6 or 7 or 5
33. primary health care/
34. general practitioners/
35. family medicine/
36. family physicians/
37. primary health care.tw.
38. primary healthcare.tw.
39. primary care.tw.
40. family practic*.tw.
41. (family adj2 (physician? or doctor? or clinic?)).tw.
42. general practi*.tw.
43. family medical care.tw.
44. gp.ti,ab.
45. or/33–44
46. exp statistical validity/
47. (sensitivity or specificity).ti.
48. (accura$ or inaccur$ or valid$ or reliability or completeness or consistency).ti.
49. under reporting.ti.
50. underreporting.ti.
51. exp statistical analysis/
52. psychometrics/
53. or/46–52
54. or/46–50
55. at risk populations/ or predisposition/ or “susceptibility (disorders)”/
56. anamnesis.ti,ab.
57. ((family or familial) adj3 (histor$ or history-taking or risk$)).ti.
58. (human adj2 pedigree).ti,ab.
59. (family history adj3 (taking or collect$ or tool? or questionnaire? or form? or algorith?m or assessment)).ti,ab.
60. (familial history adj3 (taking or collect$ or tool? or questionnaire? or form? or algorith?m or assessment)).ti,ab.
61. (genetic adj2 (risk adj3 (assessment or evaluation))).ti,ab.
62. ((first or second) adj2 degree relative?).ti,ab.
63. ((parental or paternal or maternal) adj2 history).ti.
64. or/55–63
65. 53 or 32 or 45
66. 64 and 65
67. limit 66 to human
68. limit 67 to english language
69. limit 68 to (abstract collection or bibliography or “column/opinion” or “comment/reply” or editorial or encyclopedia entry or letter)
70. 68 not 69
71. limit 70 to yr=“1995 – 2008”

### CCTR

1. Ambulatory care/
2. ambulatory care.tw.
3. Primary health care/
4. Physicians, family/
5. Family practice/
6. primary health care.tw.
7. primary healthcare.tw.
8. primary care.tw.
9. general practi*.tw.
10. family practic*.tw.
11. (family adj2 (physician? or doctor? or clinic?)).tw.
12. family medical care.tw.
13. gp.ti,ab.
14. Community health services/
15. or/1–14
16. exp Pedigree/
17. limit 16 to humans
18. Medical History Taking/
19. Genetic Predisposition to Disease/
20. anamnesis.ti,ab.
21. ((family or familial) adj3 (histor$ or history-taking or risk$)).ti.
22. (human adj2 pedigree).ti,ab.
23. Family Health/
24. (family history adj3 (taking or collect$ or tool? or questionnaire? or form? or algorith?m or assessment)).ti,ab.
25. (familial history adj3 (taking or collect$ or tool? or questionnaire? or form? or algorith?m or assessment)).ti,ab.
26. (genetic adj2 (risk adj3 (assessment or evaluation))).ti,ab.
27. ((first or second) adj2 degree relative?).ti,ab.
28. ((parental or paternal or maternal) adj2 history).ti.
29. or/17–28
30. (sensitivity or specificity).ti.
31. (accura$ or inaccur$ or valid$ or reliability).ti.
32. under reporting.ti.
33. underreporting.ti.
34. exp “Reproducibility of Results”/
35. completeness.ti.
36. consistency.ti.
37. or/30–36
38. Risk factors.ti.
39. *risk factors/
40. or/38–39
41. family history.tw.
42. 41 and 40
43. exp Cerebrovascular Accident/ge, ep, pc, et [Genetics, Epidemiology, Prevention & Control, Etiology]
44. (stroke$ or cerebrovascular$ or cerebral vascular or CVA$).ti.
45. ((cerebral or cerebellar or brainstem or vertebrobasilar) adj5 (infarct$ or isch?emi$ or thrombo$ or apoplexy or emboli$)).ti.
46. ((cerebral or intracerebral or intracranial or parenchymal or brain or intraventricular or brainstem or cerebellar or infratentorial or supratentorial or subarachnoid) adj (haemorrhage or hemorrhage or haematoma or hematoma or bleeding or aneurysm)).ti.
47. or/43–46
48. Asthma/ge, pc, et, ep [Genetics, Prevention & Control, Etiology, Epidemiology]
49. (asthma or atopy or atopic).ti.
50. or/48–49
51. Depression/pc, ep, ge, et [Prevention & Control, Epidemiology, Genetics, Etiology]
52. Depressive Disorder, Major/pc, ep, et, ge [Prevention & Control, Epidemiology, Etiology, Genetics]
53. (involutional adj2 (depress$ or psychos$ or melancholia)).ti.
54. ((major or chronic) adj2 depress$).ti.
55. or/51–54
56. Diabetes Mellitus/et, pc, ge, ep [Etiology, Prevention & Control, Genetics, Epidemiology]
57. exp Diabetes Mellitus, Type 1/ge, ep, pc, et [Genetics, Epidemiology, Prevention & Control, Etiology]
58. exp Diabetes Mellitus, Type 2/ge, ep, pc, et [Genetics, Epidemiology, Prevention & Control, Etiology]
59. (diabetes or diabetic?).ti.
60. or/56–59
61. ((breast or ovar$ or prostate or colon or colorectal or lung) adj3 (cancer$ or neoplasm$ or carcinom$ or tumo?r$)).ti.
62. exp Breast Neoplasms/et, ge, ep, pc [Etiology, Genetics, Epidemiology, Prevention & Control]
63. exp Colorectal Neoplasms/ge, pc, et, ep [Genetics, Prevention & Control, Etiology, Epidemiology]
64. exp Ovarian Neoplasms/et, ge, ep, pc [Etiology, Genetics, Epidemiology, Prevention & Control]
65. exp Prostatic Neoplasms/et, ge, ep, pc [Etiology, Genetics, Epidemiology, Prevention & Control]
66. exp Lung Neoplasms/et, ge, ep, pc [Etiology, Genetics, Epidemiology, Prevention & Control]
67. or/61–66
68. exp Cardiovascular Diseases/pc, ge, ep, et [Prevention & Control, Genetics, Epidemiology, Etiology]
69. chd.ti.
70. thrombo$.ti.
71. ((coronary or heart or cardiovascular) adj2 disease?).ti.
72. or/68–71
73. 60 or 67 or 55 or 50 or 72 or 47
74. 73 or 15 or 37
75. 29 and 74
76. 75 or 42
77. limit 76 to yr=“1995 – 2008”