# Appendixes

Appendix A Search Strategies Detailed

Appendix B Forms

Appendix C Evidence Tables and Figures

Appendix D Excluded Studies

Appendix E Technical Expert Panel and Peer Reviewers