# Acknowledgments

The researchers at the Evidence-based Practice Center would like to acknowledge the following people for their contributions.

We are grateful to our Task Officer, Supriya Janakiraman and members of the technical expert panel, Al Berg (Panel Chair), Wylie Burke, Lisa Madlensky, and Louise Acheson who were instrumental in defining the parameters of this review. We would also like to acknowledge Gurvaneet Randhawa who was a member of the Technical Expert Panel and a peer reviewer.

We would also like to thank those who worked so conscientiously, screening citations, abstracting data, preparing figures and editing the report: Carolyn Archer, Lynda Booker, Roxanne Cheeseman, Connie Freeborn, Jeffrey Freeborn, Lois Freeman-Collins, Mary Gauld, Homa Keshavarz, Jinhui Ma, Sandra McIsaac, Michelle Penta, Maureen Rice, Cecile Royer, Carolina Ruiz-Culebro, Catherine Salmon, Robert Stevens, Kate Walker, Rachel Morris, Laura Cross-Bardell, and Silvia Visentin.