# References and Included Studies

(Note that there is a separate set of references at the end of the evidence tables in Appendix F. The reference numbers there are different from those in the text of the report.)

1 Krag DN, Anderson SJ, Julian TB, et al. Technical outcomes of sentinel-lymph-node resection and conventional axillary-lymph-node dissection in patients with clinically node-negative breast cancer: results from the NSABP B-32 randomised phase III trial. Lancet Oncol. Oct. 2007;8(10):881-8. [pmid: 17851130].
2 Rosner D, Bedwani RN, Vana J, et al. Noninvasive breast carcinoma: results of a national survey by the American College of Surgeons. Ann Surg. Aug. 1980;192(2):139-47. [pmid: 6250497].
3 Brinton LA, Sherman ME, Carreon JD, et al. Recent trends in breast cancer among younger women in the United States. J Natl Cancer Inst. Nov 19. 2008;100(22):1643-8. [pmid: 19001605].
4 Ries LaG, Melbert D, Krapcho M, et al. SEER Cancer Statistics Review, 1975-2005. Bethesda, MD. National Cancer Institute. 2008. http://seer.cancer.gov/csr/1975_2005/.
5 Ernster VL, Barclay J, Kerlikowske K, et al. Mortality among women with ductal carcinoma in situ of the breast in the population-based surveillance, epidemiology and end results program. Arch Intern Med. Apr 10. 2000;160(7):953-8. [pmid: 10761960].
6 Fisher ER, Land SR, Saad RS, et al. Pathologic variables predictive of breast events in patients with ductal carcinoma in situ. Am J Clin Pathol. Jul. 2007;128(1):86-91. [pmid: 17580274].
7 Yen MF, Tabar L, Vitak B, et al. Quantifying the potential problem of overdiagnosis of ductal carcinoma in situ in breast cancer screening. Eur J Cancer. Aug. 2003;39(12):1746-54. [pmid: 12888370].
8 Duffy SW, Agbaje O, Tabar L, et al. Overdiagnosis and overtreatment of breast cancer: estimates of overdiagnosis from two trials of mammographic screening for breast cancer. Breast Cancer Res. 2005;7(6):258-65. [pmid: 16457701].
9 Bruening W, Schoelles K, Treadwell J, et al. Comparative effectiveenss of core needle and open surgical biopsy for the diagnosis of breast lesions. Rockville, MD. Prepared by ECRI Institute for the Agency for Healthcare Research and Quality under contract No. 290-02-0019; Comparative Effectiveness Review. September. 2008.
10 NIH consensus conference. Treatment of early-stage breast cancer. JAMA. Jan. 16. 1991;265(3):391-5. [pmid: 1984541].
11 Veronesi U, Saccozzi R, Del Vecchio M, et al. Comparing radical mastectomy with quadrantectomy, axillary dissection, and radiotherapy in patients with small cancers of the breast. N Engl J Med. Jul 2. 1981;305(1):6-11. [pmid: 7015141].
12 Sarrazin D, Le M, Rouesse J, et al. Conservative treatment versus mastectomy in breast cancer tumors with macroscopic diameter of 20 millimeters or less. The experience of the Institut Gustave-Roussy. Cancer. Mar 1. 1984;53(5):1209-13. [pmid: 6362840].
13 Fisher B, Bauer M, Margolese R, et al. Five-year results of a randomized clinical trial comparing total mastectomy and segmental mastectomy with or without radiation in the treatment of breast cancer. N Engl J Med. Mar 14. 1985;312(11):665-73. [pmid: 3883167].
14 Veronesi U, Banfi A, Del Vecchio M, et al. Comparison of Halsted mastectomy with quadrantectomy, axillary dissection, and radiotherapy in early breast cancer: long-term results. Eur J Cancer Clin Oncol. Sep. 1986;22(9):1085-9. [pmid: 3536526].
15 Sarrazin D, Le MG, Arriagada R, et al. Ten-year results of a randomized trial comparing a conservative treatment to mastectomy in early breast cancer. Radiother Oncol. Mar. 1989;14(3):177-84. [pmid: 2652199].
16 Fisher B, Redmond C, Poisson R, et al. Eight-year results of a randomized clinical trial comparing total mastectomy and lumpectomy with or without irradiation in the treatment of breast cancer. N Engl J Med. Mar 30. 1989;320(13):822-8. [pmid: 2927449].
17 Baxter NN, Virnig BA, Durham SB, et al. Trends in the treatment of ductal carcinoma in situ of the breast. J Natl Cancer Inst. Mar 17. 2004;96(6):443-8. [pmid: 15026469].
18 National Library of Medicine (U.S.), National Institutes of Health (U.S.). PubMed Central. PubMed Central [digital]. Bethesda, MD. National Library of Medicine. 2000.
19 Elsevier Science (Firm). Scirus, for scientific information only. Amsterdam. Elsevier Science. 2001.
20 Cochrane Library.
21 Higgins J, Green S. Cochrane Collaboration Cochrane handbook for systematic reviews of interventions. Chichester, West Sussex ; Hoboken NJ. John Wiley & Sons. 2008.
22 Hudis CA, Barlow WE, Costantino JP, et al. Proposal for standardized definitions for efficacy end points in adjuvant breast cancer trials: the STEEP system. J Clin Oncol. May 20. 2007;25(15):2127-32. [pmid: 17513820].
23 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
24 Atkins D, Eccles M, Flottorp S, et al. Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. Dec 22. 2004;4(1):38. [pmid: 15615589].
25 Atkins D, Briss PA, Eccles M, et al. Systems for grading the quality of evidence and the strength of recommendations II: pilot study of a new system. BMC Health Serv Res. Mar 23. 2005;5(1):25. [pmid: 15788089].
26 Agency for Healthcare Research and Quality. University of California-San Francisco-Stanford Evidence-Based Practice Center. Systems to Rate the Strength of Scientific Evidence. Rockville, MD. 2002.
27 Aschengrau A, Seage GR. Essentials of Epidemiology in Public Health. Sudbury, Mass. Jones and Bartlett. 2003.
28 Dawson B, Trapp RG. Basic & Clinical Biostatistics (LANGE Basic Science). 3rd ed. New York. Lange Medical Books-McGraw-Hill. 2004.
29 Al-Marzouki S, Evans S, Marshall T, et al. Are these data real? Statistical methods for the detection of data fabrication in clinical trials. BMJ. Jul 30. 2005;331(7511):267-70. [pmid: 16052019].
30 Buyse M, George SL, Evans S, et al. The role of biostatistics in the prevention, detection and treatment of fraud in clinical trials. Statistics in Medicine. 1999;18(24):3435-51. [pmid: 10611617].
31 Kahn HA, Sempos CT. Statistical Methods in Epidemiology (Monographs in Epidemiology and Biostatistics). USA. Oxford University Press. 1989.
32 Whitehead A. Meta-analysis of controlled clinical trials. Chichester, New York. John Wiley & Sons. 2002.
33 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
34 Moher D, Cook DJ, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. Nov 27. 1999;354(9193):1896-900. [pmid: 10584742].
35 Stroup DF, Berlin JA, Morton SC, et al. Meta-analysis of observational studies in epidemiology: a proposal for reporting. Meta-analysis Of Observational Studies in Epidemiology (MOOSE) group. JAMA. Apr 19. 2000;283(15):2008-12. [pmid: 10789670].
36 Viechtbauer W. Confidence intervals for the amount of heterogeneity in meta-analysis. Stat Med. 2006. Feb. 6.
37 Knapp G, Biggerstaff BJ, Hartung J. Assessing the amount of heterogeneity in random-effects meta-analysis. Biom J. Apr. 2006;48(2):271-85. [pmid: 16708778].
38 Egger M, Smith GD, Altman DG. Systematic Reviews in Health Care. London. NetLibrary, Inc. BMJ Books. 2001.
39 Ebrahim S. The use of numbers needed to treat derived from systematic reviews and meta-analysis. Caveats and pitfalls. Eval Health Prof. Jun. 2001;24(2):152-64. [pmid: 11523384].
40 Higgins J, Green S. The Cochrane Collaboration The Cochrane handbook for systematic reviews of interventions. John Wiley & Sons, Ltd. Cochrane Collaboration. Available at: http://www.cochrane.org/resources/handbook/handbook.pdf. 2006.
41 Egger M, Smith GD. Bias in location and selection of studies. BMJ. Jan 3. 1998;316(7124):61-6. [pmid: 9451274].
42 Dickersin K, Min YI. NIH clinical trials and publication bias. Online J Curr Clin Trials. 1993. Apr. 28. Doc No 50:[4967 words; 53 paragraphs].
43 Thornton A, Lee P. Publication bias in meta-analysis: its causes and consequences. J Clin Epidemiol. Feb. 2000;53(2):207-16. [pmid: 10729693].
44 Lewis JD, Milbrath JR, Shaffer KA, et al. Implications of suspicious findings in breast cancer screening. Arch Surg. Aug. 1975;110(8):903-7. [pmid: 168837].
45 Schwartz GF, Feig SA, Libshitz HI, et al. Mass screening for breast disease. Results, problems, and expectations. Obstet Gynecol. Aug. 1976;48(2):137-41. [pmid: 181701].
46 Feig SA, Shaber GS, Patchefsky A, et al. Analysis of clinically occult and mammographically occult breast tumors. AJR Am J Roentgenol. Mar. 1977;128(3):403-8. [pmid: 190908].
47 Croll J, MacMillan IS, Ryan J. Screening for breast cancer by mammography: an Australian experience. Med J Aust. Feb. 26. 90. 1977;1(9):287-2. [pmid: 192986].
48 Patchefsky AS, Shaber GS, Schwartz GF, et al. The pathology of breast cancer detected by mass population screening. Cancer. Oct. 1977;40(4):1659-70. [pmid: 907976].
49 Kreger BE, Splansky GL, Schatzkin A. The cancer experience in the Framingham Heart Study cohort. Cancer. Jan 1. 1991;67(1):1-6. [pmid: 1845934].
50 Curpen BN, Sickles EA, Sollitto RA, et al. The comparative value of mammographic screening for women 40–49 years old versus women 50–64 years old. AJR Am J Roentgenol. May. 1995;164(5):1099-103. [pmid: 7717212].
51 Tabar L, Fagerberg G, Chen HH, et al. Efficacy of breast cancer screening by age. New results from the Swedish Two-County Trial. Cancer. 1995;05/15; 75(10):2507-17.
52 Faulk RM, Sickles EA, Sollitto RA, et al. Clinical efficacy of mammographic screening in the elderly. Radiology. Jan. 1995;194(1):193-7. [pmid: 7997552].
53 Garas I, Pateras H, Triandafilou D, et al. Breast cancer screening in southern Greece. Eur J Cancer Prev. 1994;01; 3(Suppl 1):35-9.
54 Alves JG, Cruz DB, Rodrigues VL, et al. Breast cancer screening in the central region of Portugal. Eur J Cancer Prev. 1994;01; 3(Suppl 1):49-53.
55 Van Oyen H, Verellen W. Breast cancer screening in the Flemish region, Belgium. Eur J Cancer Prev. 1994;01; 3(Suppl 1):7-12.
56 Simon MS, Lemanne D, Schwartz AG, et al. Recent trends in the incidence of in situ and invasive breast cancer in the Detroit metropolitan area (1975–1988). Cancer. Feb 1. 1993;71(3):769-74. [pmid: 8431859].
57 Tabar L, Fagerberg G, Chen HH, et al. Tumour development, histology and grade of breast cancers: prognosis and progression. Int J Cancer. May 16. 1996;66(4):413-9. [pmid: 8635853].
58 Kerlikowske K, Grady D, Barclay J, et al. Effect of age, breast density, and family history on the sensitivity of first screening mammography. JAMA. Jul 3. 1996;276(1):33-8. [pmid: 8667536].
59 Zheng T, Holford TR, Chen Y, et al. Time trend of female breast carcinoma in situ by race and histology in Connecticut, USA. Eur J Cancer. Jan. 1997;33(1):96-100. [pmid: 9071907].
60 Evans WP 3rd, Starr AL, Bennos ES. Comparison of the relative incidence of impalpable invasive breast carcinoma and ductal carcinoma in situ in cancers detected in patients older and younger than 50 years of age. Radiology. Aug. 1997;204(2):489-91. [pmid: 9240541].
61 Levi F, Te VC, Randimbison L, et al. Trends of in situ carcinoma of the breast in Vaud, Switzerland. Eur J Cancer. May. 1997;33(6):903-6. [pmid: 9291813].
62 Vizcaino I, Salas D, Vilar JS, et al. Breast cancer screening: first round in the population-based program in Valencia, Spain. Collaborative Group of Readers of the Breast Cancer Screening Program of the Valencia Community. Radiology. Jan. 1998;206(1):253-60. [pmid: 9423680].
63 Kitchen PR, Cawson JN, Winch KL, et al. Characteristics and treatment of breast cancers 10 mm or less detected by a mammographic screening programme. Aust N Z J Surg. Jan. 1998;68(1):45-9. [pmid: 9440456].
64 Fracheboud J, de Koning HJ, Beemsterboer PM, et al. Nation-wide breast cancer screening in The Netherlands: results of initial and subsequent screening 1990–1995. National Evaluation Team for Breast Cancer Screening. Int J Cancer. Mar 2. 1998;75(5):694-8. [pmid: 9495236].
65 Chan LK, Lam HS, Chan ES, et al. Mammogram screening of Chinese women in Kwong Wah Hospital, Hong Kong. Australas Radiol. Feb. 1998;42(1):6-9. [pmid: 9509595].
66 Dershaw DD, Loring L, True SJ, et al. A comparison of screening mammography results from programs for women of different socioeconomic status. Cancer. May 1. 1998;82(9):1692-7. [pmid: 9576290].
67 Barchielli A, Paci E, Giorgi D. Recent trends of in situ carcinoma of the breast and mammographic screening in the Florence area, Italy. Cancer Causes Control. Aug. 1999;10(4):313-7. [pmid: 10482490].
68 Trentham-Dietz A, Newcomb PA, Storer BE, et al. Risk factors for carcinoma in situ of the breast. Cancer Epidemiol Biomarkers Prev. Jul. 2000;9(7):697-703. [pmid: 10919740].
69 Warren R, Duffy S. Interval cancers as an indicator of performance in breast screening. Breast Cancer. Jan. 2000;7(1):9-18. [pmid: 11029765].
70 Kerlikowske K, Carney PA, Geller B, et al. Performance of screening mammography among women with and without a first-degree relative with breast cancer. Ann Intern Med. Dec 5. 2000;133(11):855-63. [pmid: 11103055].
71 Walter LC, Eng C, Covinsky KE. Screening mammography for frail older women: what are the burdens?. J Gen Intern Med. Nov. 2001;16(11):779-84. [pmid: 11722693].
72 Ernster VL, Ballard-Barbash R, Barlow WE, et al. Detection of ductal carcinoma in situ in women undergoing screening mammography. J Natl Cancer Inst. Oct 16. 2002;94(20):1546-54. [pmid: 12381707].
73 Innos K, Horn-Ross PL. Recent trends and racial/ethnic differences in the incidence and treatment of ductal carcinoma in situ of the breast in California women. Cancer. Feb 15. 2003;97(4):1099-106. [pmid: 12569612].
74 Schootman M, Kinman E, Farria D. Rural-urban differences in ductal carcinoma in situ as a proxy for mammography use over time. J Rural Health. Fall. 2003;19(4):470-6. [pmid: 14526505].
75 Smith-Bindman R, Chu PW, Miglioretti DL, et al. Comparison of screening mammography in the United States and the United kingdom. JAMA. Oct 22. 2003;290(16):2129-37. [pmid: 14570948].
76 Kricker A, Goumas C, Armstrong B. Ductal carcinoma in situ of the breast, a population-based study of epidemiology and pathology. Br J Cancer. Apr 5. 2004;90(7):1382-5. [pmid: 15054459].
77 Coburn NG, Chung MA, Fulton J, et al. Decreased breast cancer tumor size, stage, and mortality in Rhode Island: an example of a well-screened population. Cancer Control. Jul-Aug. 2004;11(4):222-30. [pmid: 15284713].
78 Fracheboud J, Otto SJ, van Dijck JA, et al. Decreased rates of advanced breast cancer due to mammography screening in The Netherlands. Br J Cancer. 2004;08/31; 91(5):861-7. [pmid: 14710223].
79 Erbas B, Amos A, Fletcher A, et al. Incidence of invasive breast cancer and ductal carcinoma in situ in a screening program by age: should older women continue screening?. Cancer Epidemiol Biomarkers Prev. Oct. 2004;13(10):1569-73. [pmid: 15466971].
80 Anderson WF, Chu KC, Devesa SS. Distinct incidence patterns among in situ and invasive breast carcinomas,with possible etiologic implications. Breast Cancer Res Treat. Nov. 2004;88(2):149-59. [pmid: 15564798].
81 Smith-Bindman R, Ballard-Barbash R, Miglioretti DL, et al. Comparing the performance of mammography screening in the USA and the UK. J Med Screen. 2005;12(1):50-4. [pmid: 15814020].
82 Li CI, Daling JR, Malone KE. Age-specific incidence rates of in situ breast carcinomas by histologic type, 1980 to 2001. Cancer Epidemiol Biomarkers Prev. Apr. 2005;14(4):1008-11. [pmid: 15824180].
83 Barchielli A, Federico M, De Lisi V, et al. In situ breast cancer: incidence trend and organised screening programmes in Italy. Eur J Cancer. May. 2005;41(7):1045-50. [pmid: 15862754].
84 Leach MO, Boggis CR, Dixon AK, et al. Screening with magnetic resonance imaging and mammography of a UK population at high familial risk of breast cancer: a prospective multicentre cohort study (MARIBS). Lancet. May. 21–27. 2005;365(9473):1769-78. [pmid: 15910949].
85 Weaver DL, Vacek PM, Skelly JM, et al. Predicting biopsy outcome after mammography: what is the likelihood the patient has invasive or in situ breast cancer?. Ann Surg Oncol. Aug. 2005;12(8):660-73. [pmid: 15968496].
86 Blanks RG, Bennett RL, Patnick J, et al. The effect of changing from one to two views at incident (subsequent) screens in the NHS breast screening programme in England: impact on cancer detection and recall rates. Clin Radiol. 2005;06; 60(6):674-80.
87 Birdwell RL, Bandodkar P, Ikeda DM. Computer-aided detection with screening mammography in a university hospital setting. Radiology. Aug. 2005;236(2):451-7. [pmid: 16040901].
88 Kerlikowske K, Creasman J, Leung JW, et al. Differences in screening mammography outcomes among White, Chinese, and Filipino women. Arch Intern Med. Sep 12. 2005;165(16):1862-8. [pmid: 16157830].
89 Weaver DL, Rosenberg RD, Barlow WE, et al. Pathologic findings from the Breast Cancer Surveillance Consortium: population-based outcomes in women undergoing biopsy after screening mammography. Cancer. Feb 15. 2006;106(4):732-42. [pmid: 16411214].
90 Kumar AS, Bhatia V, Henderson IC. Overdiagnosis and overtreatment of breast cancer: rates of ductal carcinoma in situ: a US perspective. Breast Cancer Res. 2005;7(6):271-5. [pmid: 16457703].
91 Nekhlyudov L, Kroenke CH, Jung I, et al. Prospective changes in quality of life after ductal carcinoma-in-situ: results from the Nurses’ Health Study. J Clin Oncol. Jun 20. 2006;24(18):2822-7. [pmid: 16782920].
92 Gill JK, Maskarinec G, Pagano I, et al. The association of mammographic density with ductal carcinoma in situ of the breast: the Multiethnic Cohort. Breast Cancer Res. 2006;8(3):R30. [pmid: 16796758].
93 Rakovitch E, Pignol JP, Chartier C, et al. The management of ductal carcinoma in situ of the breast: a screened population-based analysis. Breast Cancer Res Treat. Mar. 2007;101(3):335-47. [pmid: 16838110].
94 Yeoh KG, Chew L, Wang SC. Cancer screening in Singapore, with particular reference to breast, cervical and colorectal cancer screening. J Med Screen. 2006;13(Suppl 1):S14-9. [pmid: 17227636].
95 Sumner WE 3rd, Koniaris LG, Snell SE, et al. Results of 23,810 cases of ductal carcinoma-in-situ. Ann Surg Oncol. May. 2007;14(5):1638-43. [pmid: 17245612].
96 Boncz I, Sebestyen A, Dobrossy L, et al. The organisation and results of first screening round of the Hungarian nationwide organised breast cancer screening programme. Ann Oncol. Apr. 2007;18(4):795-9. [pmid: 17259642].
97 Kerlikowske K, Ichikawa L, Miglioretti DL, et al. Longitudinal measurement of clinical mammographic breast density to improve estimation of breast cancer risk. J Natl Cancer Inst. Mar 7. 2007;99(5):386-95. [pmid: 17341730].
98 Moran CJ, Kell MR, Flanagan FL, et al. Role of sentinel lymph node biopsy in high-risk ductal carcinoma in situ patients. Am J Surg. Aug. 2007;194(2):172-5. [pmid: 17618799].
99 MacKenzie TA, Titus-Ernstoff L, Vacek PM, et al. Breast density in relation to risk of ductal carcinoma in situ of the breast in women undergoing screening mammography. Cancer Causes Control. Nov. 2007;18(9):939-45. [pmid: 17638106].
100 Vigeland E, Klaasen H, Klingen TA, et al. Full-field digital mammography compared to screen film mammography in the prevalent round of a population-based screening programme: the Vestfold County Study. Eur Radiol. Jan. 2008;18(1):183-91. [pmid: 17680246].
101 Kerlikowske K, Miglioretti DL, Buist DS, et al. Declines in invasive breast cancer and use of postmenopausal hormone therapy in a screening mammography population. J Natl Cancer Inst. Sep 5. 2007;99(17):1335-9. [pmid: 17698950].
102 Hofvind S, Sorum R, Thoresen S. Incidence and tumor characteristics of breast cancer diagnosed before and after implementation of a population-based screening-program. Acta Oncol. 2008;47(2):225-31. [pmid: 17851868].
103 Yu J, Park A, Morris E, et al. MRI screening in a clinic population with a family history of breast cancer. Ann Surg Oncol. Feb. 2008;15(2):452-61. [pmid: 18026801].
104 Tuncbilek I, Ozdemir A, Gultekin S, et al. Clinical outcome assessment in mammography: an audit of 7,506 screening and diagnostic mammography examinations. Diagn Interv Radiol. Dec. 2007;13(4):183-7. [pmid: 18092288].
105 Cuzick J, Forbes J, Edwards R, et al. First results from the International Breast Cancer Intervention Study (IBIS-I): a randomised prevention trial. Lancet. Sep 14. 2002;360(9336):817-24. [pmid: 12243915].
106 Cuzick J, Forbes JF, Sestak I, et al. Long-term results of tamoxifen prophylaxis for breast cancer--96-month follow-up of the randomized IBIS-I trial. J Natl Cancer Inst. Feb 21. 2007;99(4):272-82. [pmid: 17312304].
107 Powles TJ, Ashley S, Tidy A, et al. Twenty-year follow-up of the Royal Marsden randomized, double-blinded tamoxifen breast cancer prevention trial. J Natl Cancer Inst. Feb 21. 2007;99(4):283-90. [pmid: 17312305].
108 Reeves GK, Beral V, Green J, et al. Hormonal therapy for menopause and breast-cancer risk by histological type: a cohort study and meta-analysis. Lancet Oncol. Nov. 2006;7(11):910-8. [pmid: 17081916].
109 Gapstur SM, Morrow M, Sellers TA. Hormone replacement therapy and risk of breast cancer with a favorable histology: results of the Iowa Women’s Health Study. JAMA. Jun 9. 1999;281(22):2091-7. [pmid: 10367819].
110 Johnson TW, Anderson KE, Lazovich D, et al. Association of Aspirin and Nonsteroidal Anti-inflammatory Drug Use. Cancer Epidemiology, Biomarkers & Prevention. 2007;11:1586-91.
111 Wohlfahrt J, Rank F, Kroman N, et al. A comparison of reproductive risk factors for CIS lesions and invasive breast cancer. Int J Cancer. Feb 20. 2004;108(5):750-3. [pmid: 14696102].
112 Kerlikowske K, Miglioretti DL, Ballard-Barbash R, et al. Prognostic characteristics of breast cancer among postmenopausal hormone users in a screened population. J Clin Oncol. Dec 1. 2003;21(23):4314-21. [pmid: 14645420].
113 Frank TS, Deffenbaugh AM, Reid JE, et al. Clinical characteristics of individuals with germline mutations in BRCA1 and BRCA2: analysis of 10,000 individuals. J Clin Oncol. Mar 15. 2002;20(6):1480-90. [pmid: 11896095].
114 Zeleniuch-Jacquotte A, Gu Y, Shore RE, et al. Postmenopausal levels of sex hormones and risk of breast carcinoma in situ: results of a prospective study. Int J Cancer. Mar 20. 2005;114(2):323-7. [pmid: 15540225].
115 Elmore JG, Moceri VM, Carter D, et al. Breast carcinoma tumor characteristics in black and white women. Cancer. Dec 15. 1998;83(12):2509-15. [pmid: 9874456].
116 Kerlikowske K, Barclay J, Grady D, et al. Comparison of risk factors for ductal carcinoma in situ and invasive breast cancer. J Natl Cancer Inst. Jan 1. 1997;89(1):76-82. [pmid: 8978410].
117 Chen CY, Sun LM, Anderson BO. Paget disease of the breast: changing patterns of incidence, clinical presentation, and treatment in the U.S. Cancer. Oct 1. 2006;107(7):1448-58. [pmid: 16933329].
118 Vamre TB, Stalsberg H, Thomas DB. Extra-tumoral breast tissue in breast cancer patients: variations with steroid contraceptive use. Int J Cancer. Jun 1. 2006;118(11):2827-31. [pmid: 16380999].
119 Elkhadrawy TM, Ahsan H, Neugut AI. Serum cholesterol and the risk of ductal carcinoma in situ: a case-control study. Eur J Cancer Prev. Oct. 1998;7(5):393-6. [pmid: 9884885].
120 Claus EB, Stowe M, Carter D. Breast carcinoma in situ: risk factors and screening patterns. J Natl Cancer Inst. Dec 5. 2001;93(23):1811-7. [pmid: 11734598].
121 Bohlke K, Cramer DW, Trichopoulos D, et al. Insulin-like growth factor-I in relation to premenopausal ductal carcinoma in situ of the breast. Epidemiology. Sep. 1998;9(5):570-3. [pmid: 9730040].
122 Nichols HB, Trentham-Dietz A, Egan KM, et al. Oral contraceptive use and risk of breast carcinoma in situ. Cancer Epidemiol Biomarkers Prev. Nov. 2007;16(11):2262-8. [pmid: 18006914].
123 Weiss HA, Brinton LA, Brogan D, et al. Epidemiology of in situ and invasive breast cancer in women aged under 45. Br J Cancer. May. 1996;73(10):1298-305. [pmid: 8630296].
124 Patel AV, Press MF, Meeske K, et al. Lifetime recreational exercise activity and risk of breast carcinoma in situ. Cancer. Nov 15. 2003;98(10):2161-9. [pmid: 14601085].
125 Claus EB, Stowe M, Carter D. Family history of breast and ovarian cancer and the risk of breast carcinoma in situ. Breast Cancer Res Treat. Mar. 2003;78(1):7-15. [pmid: 12611452].
126 Claus EB, Stowe M, Carter D. Oral contraceptives and the risk of ductal breast carcinoma in situ. Breast Cancer Res Treat. Sep. 2003;81(2):129-36. [pmid: 14572155].
127 Stacey SN, Manolescu A, Sulem P, et al. Common variants on chromosome 5p12 confer susceptibility to estrogen receptor-positive breast cancer. Nat Genet. Jun. 2008;40(6):703-6. [pmid: 18438407].
128 Granstrom C, Sundquist J, Hemminki K. Population attributable risks for breast cancer in Swedish women by morphological type. Breast Cancer Research & Treatment. Oct. 2008;111(3):559-68. [pmid: 17990099].
129 Roberts MM, Alexander FE, Anderson TJ, et al. The Edinburgh randomised trial of screening for breast cancer: description of method. Br J Cancer. Jul. 1984;50(1):1-6. [pmid: 6743506].
130 Frisell J, Lidbrink E, Hellstrom L, et al. Followup after 11 years--update of mortality results in the Stockholm mammographic screening trial. Breast Cancer Res Treat. Sep. 1997;45(3):263-70. [pmid: 9386870].
131 Miller AB, To T, Baines CJ, et al. Canadian National Breast Screening Study-2: 13-year results of a randomized trial in women aged 50–59 years. J Natl Cancer Inst. Sep 20. 2000;92(18):1490-9. [pmid: 10995804].
132 Miller AB, To T, Baines CJ, et al. The Canadian National Breast Screening Study-1: breast cancer mortality after 11 to 16 years of follow-up. A randomized screening trial of mammography in women age 40 to 49 years. Ann Intern Med. Sep 3. 2002;137(5 Part 1):305-12. [pmid: 12204013].
133 Bjurstam N, Bjorneld L, Warwick J, et al. The Gothenburg Breast Screening Trial. Cancer. May 15. 2003;97(10):2387-96. [pmid: 12733136].
134 Shapiro S. Periodic screening for breast cancer: the HIP Randomized Controlled Trial. Health Insurance Plan J Natl Cancer Inst Monogr. 1997:27-30.
135 Zackrisson S, Andersson I, Janzon L, et al. Rate of over-diagnosis of breast cancer 15 years after end of Malmo mammographic screening trial: follow-up study. Bmj. Mar 25. 2006;332(7543):689-92. [pmid: 16517548].
136 Duffy SW, Tabar L, Vitak B, et al. The relative contributions of screen-detected in situ and invasive breast carcinomas in reducing mortality from the disease. Eur J Cancer. Aug. 2003;39(12):1755-60. [pmid: 12888371].
137 Chlebowski RT, Hendrix SL, Langer RD, et al. Influence of estrogen plus progestin on breast cancer and mammography in healthy postmenopausal women: the Women’s Health Initiative Randomized Trial. Jama. Jun 25. 2003;289(24):3243-53. [pmid: 12824205].
138 Breast cancer and hormone replacement therapy: collaborative reanalysis of data from 51 epidemiological studies of 52,705 women with breast cancer and 108,411 women without breast cancer. Collaborative Group on Hormonal Factors in Breast Cancer. Lancet. Oct. 11. 1997;350(9084):1047-59. [pmid: 10213546].
139 Kerlikowske K, Walker R, Miglioretti DL, et al. Obesity, mammography use and accuracy, and advanced breast cancer risk. J Natl Cancer Inst. Dec 3. 2008;100(23):1724-33. [pmid: 19033562].
140 Saetersdal A, Dorum A, Heimdal K, et al. Inherited predisposition to breast carcinoma. Results of first round examination of 537 women at risk. Anticancer Res. Jul-Aug. 1996;16(4A):1989-92. [pmid: 8712731].
141 Moller P, Maehle L, Heimdal K, et al. Inherited breast carcinoma--prospective findings in 1,194 women at risk. Acta Oncol. 1996;35(Suppl 8):7-11. [pmid: 9073043].
142 Chart PL, Franssen E. Management of women at increased risk for breast cancer: preliminary results from a new program. Cmaj. Nov 1. 1997;157(9):1235-42. [pmid: 9361645].
143 Lalloo F, Boggis CR, Evans DG, et al. Screening by mammography, women with a family history of breast cancer. Eur J Cancer. May. 1998;34(6):937-40. [pmid: 9797712].
144 Kollias J, Sibbering DM, Blamey RW, et al. Screening women aged less than 50 years with a family history of breast cancer. Eur J Cancer. May. 1998;34(6):878-83. [pmid: 9797701].
145 Tilanus-Linthorst MM, Bartels CC, Obdeijn AI, et al. Earlier detection of breast cancer by surveillance of women at familial risk. Eur J Cancer. Mar. 2000;36(4):514-9. [pmid: 10717529].
146 Brekelmans CT, Westers P, Faber JA, et al. Age specific sensitivity and sojourn time in a breast cancer screening programme (DOM) in The Netherlands: a comparison of different methods. J Epidemiol Community Health. Feb. 1996;50(1):68-71. [pmid: 8762357].
147 Brekelmans CT, Seynaeve C, Bartels CC, et al. Effectiveness of breast cancer surveillance in BRCA1/2 gene mutation carriers and women with high familial risk. J Clin Oncol. Feb 15. 2001;19(4):924-30. [pmid: 11181654].
148 Komenaka IK, Ditkoff BA, Joseph KA, et al. The development of interval breast malignancies in patients with BRCA mutations. Cancer. May 15. 2004;100(10):2079-83. [pmid: 15139048].
149 Nystrom L, Andersson I, Bjurstam N, et al. Long-term effects of mammography screening: updated overview of the Swedish randomised trials. Lancet. Mar 16. 2002;359(9310):909-19. [pmid: 11918907].
150 Tabar L, Vitak B, Chen HH, et al. The Swedish Two-County Trial twenty years later. Updated mortality results and new insights from long-term follow-up. Radiol Clin North Am. Jul. 2000;38(4):625-51. [pmid: 10943268].
151 Fisher B, Costantino JP, Wickerham DL, et al. Tamoxifen for prevention of breast cancer: report of the National Surgical Adjuvant Breast and Bowel Project P-1 Study. J Natl Cancer Inst. Sep 16. 1998;90(18):1371-88. [pmid: 9747868].
152 Vogel VG, Costantino JP, Wickerham DL, et al. Effects of tamoxifen vs raloxifene on the risk of developing invasive breast cancer and other disease outcomes: the NSABP Study of Tamoxifen and Raloxifene (STAR) P-2 trial. Jama. Jun 21. 2006;295(23):2727-41. [pmid: 16754727].
153 Martino S, Cauley JA, Barrett-Connor E, et al. Continuing outcomes relevant to Evista: breast cancer incidence in postmenopausal osteoporotic women in a randomized trial of raloxifene. J Natl Cancer Inst. Dec 1. 2004;96(23):1751-61. [pmid: 15572757].
154 Kolb TM, Lichy J, Newhouse JH. Comparison of the performance of screening mammography, physical examination, and breast US and evaluation of factors that influence them: an analysis of 27,825 patient evaluations. Radiology. Oct. 2002;225(1):165-75. [pmid: 12355001].
155 Smith RA, Saslow D, Sawyer KA, et al. American Cancer Society guidelines for breast cancer screening: update 2003. CA Cancer J Clin. May-Jun. 2003;53(3):141-69. [pmid: 12809408].
156 Gordon PB, Goldenberg SL. Malignant breast masses detected only by ultrasound. A retrospective review. Cancer. Aug 15. 1995;76(4):626-30. [pmid: 8625156].
157 Kolb TM, Lichy J, Newhouse JH. Occult cancer in women with dense breasts: detection with screening US--diagnostic yield and tumor characteristics. Radiology. Apr. 1998;207(1):191-9. [pmid: 9530316].
158 Buchberger W, DeKoekkoek-Doll P, Springer P, et al. Incidental findings on sonography of the breast: clinical significance and diagnostic workup. AJR Am J Roentgenol. Oct. 1999;173(4):921-7. [pmid: 10511149].
159 Stavros AT, Thickman D, Rapp CL, et al. Solid breast nodules: use of sonography to distinguish between benign and malignant lesions. Radiology. Jul. 1995;196(1):123-34. [pmid: 7784555].
160 O’Driscoll D, Warren R, MacKay J, et al. Screening with breast ultrasound in a population at moderate risk due to family history. J Med Screen. 2001;8(2):106-9. [pmid: 11480440].
161 Kuhl CK, Schmutzler RK, Leutner CC, et al. Breast MR imaging screening in 192 women proved or suspected to be carriers of a breast cancer susceptibility gene: preliminary results. Radiology. Apr. 2000;215(1):267-79. [pmid: 10751498].
162 Warner E, Plewes DB, Shumak RS, et al. Comparison of breast magnetic resonance imaging, mammography, and ultrasound for surveillance of women at high risk for hereditary breast cancer. J Clin Oncol. Aug 1. 2001;19(15):3524-31. [pmid: 11481359].
163 Podo F, Sardanelli F, Canese R, et al. The Italian multi-centre project on evaluation of MRI and other imaging modalities in early detection of breast cancer in subjects at high genetic risk. J Exp Clin Cancer Res. Sep. 2002;21(3 Suppl):115-24. [pmid: 12585665].
164 Kriege M, Brekelmans CT, Boetes C, et al. Efficacy of MRI and mammography for breast-cancer screening in women with a familial or genetic predisposition. N Engl J Med. Jul 29. 2004;351(5):427-37. [pmid: 15282350].
165 Warner E, Plewes DB, Hill KA, et al. Surveillance of BRCA1 and BRCA2 mutation carriers with magnetic resonance imaging, ultrasound, mammography, and clinical breast examination. JAMA. Sep 15. 2004;292(11):1317-25. [pmid: 15367553].
166 Hagen AI, Kvistad KA, Maehle L, et al. Sensitivity of MRI versus conventional screening in the diagnosis of BRCA-associated breast cancer in a national prospective series. Breast. Aug. 2007;16(4):367-74. [pmid: 17317184].
167 Hartman AR, Daniel BL, Kurian AW, et al. Breast magnetic resonance image screening and ductal lavage in women at high genetic risk for breast carcinoma. Cancer. Feb 1. 2004;100(3):479-89. [pmid: 14745863].
168 Teh W, Wilson AR. The role of ultrasound in breast cancer screening. A consensus statement by the European Group for Breast Cancer Screening. Eur J Cancer. Mar. 1998;34(4):449-50. [pmid: 9713292].
169 Kramer WM, Rush BF Jr. Mammary duct proliferation in the elderly. A histopathologic study. Cancer. Jan. 1973;31(1):130-7. [pmid: 4345607].
170 Nielsen M, Jensen J, Andersen J. Precancerous and cancerous breast lesions during lifetime and at autopsy. A study of 83 women. Cancer. Aug 15. 1984;54(4):612-5. [pmid: 6744199].
171 Alpers CE, Wellings SR. The prevalence of carcinoma in situ in normal and cancer-associated breasts. Hum Pathol. Aug. 1985;16(8):796-807. [pmid: 2991111].
172 Bhathal PS, Brown RW, Lesueur GC, et al. Frequency of benign and malignant breast lesions in 207 consecutive autopsies in Australian women. Br J Cancer. Feb. 1985;51(2):271-8. [pmid: 3966983].
173 Bartow SA, Pathak DR, Black WC, et al. Prevalence of benign, atypical, and malignant breast lesions in populations at different risk for breast cancer. A forensic autopsy study. Cancer. Dec 1. 1987;60(11):2751-60. [pmid: 3677009].
174 Nielsen M, Thomsen JL, Primdahl S, et al. Breast cancer and atypia among young and middle-aged women: a study of 110 medicolegal autopsies. Br J Cancer. Dec. 1987;56(6):814-9. [pmid: 2829956].
175 Horner MJ, Ries LAG, Krapcho M, et al., editors. SEER Cancer Statistics Review, 1975-2006. Bethesda, MD. National Cancer Institute. http://seer.cancer.gov/csr/1975_2006/, based on November 2008 SEER data submission, posted to the SEER web site. 2009.
176 Claus EB, Petruzella S, Matloff E, et al. Prevalence of BRCA1 and BRCA2 mutations in women diagnosed with ductal carcinoma in situ. JAMA. Feb 23. 2005;293(8):964-9. [pmid: 15728167].
177 Ng EH, Ng FC, Tan PH, et al. Results of intermediate measures from a population-based, randomized trial of mammographic screening prevalence and detection of breast carcinoma among Asian women: the Singapore Breast Screening Project. Cancer. Apr 15. 1998;82(8):1521-8. [pmid: 9554530].
178 Schott G, Reichel M, Junkermann H, et al. Retrospective quantification of background incidence and stage distribution of breast cancer for the mammography screening pilot project in Wiesbaden, Germany. J Cancer Res Clin Oncol. Jan. 2008;134(1):29-35. [pmid: 17602243].
179 Ohuchi N, Yoshida K, Kimura M, et al. Improved detection rate of early breast cancer in mass screening combined with mammography. Jpn J Cancer Res. Jul. 1993;84(7):807-12. [pmid: 8396569].
180 National Center for Health Statistics. United States, 2008 With Chartbook, Table 89. Hyattsville, MD. 2009.
181 Liberman L, Morris EA, Dershaw DD, et al. MR imaging of the ipsilateral breast in women with percutaneously proven breast cancer. AJR Am J Roentgenol. Apr. 2003;180(4):901-10. [pmid: 12646427].
182 Morrogh M, Morris EA, Liberman L, et al. MRI identifies otherwise occult disease in select patients with Paget disease of the nipple. J Am Coll Surg. Feb. 2008;206(2):316-21. [pmid: 18222386].
183 Solin LJ, Orel SG, Hwang WT, et al. Relationship of breast magnetic resonance imaging to outcome after breast-conservation treatment with radiation for women with early-stage invasive breast carcinoma or ductal carcinoma in situ. J Clin Oncol. Jan 20. 2008;26(3):386-91. [pmid: 18202414].
184 Hoogerbrugge N, Kamm YJ, Bult P, et al. The impact of a false-positive MRI on the choice for mastectomy in BRCA mutation carriers is limited. Ann Oncol. Apr. 2008;19(4):655-9. [pmid: 18096566].
185 Lee L, Pintilie M, Hodgson DC, et al. Screening mammography for young women treated with supradiaphragmatic radiation for Hodgkin’s lymphoma. Ann Oncol. Jan. 2008;19(1):62-7. [pmid: 17878177].
186 Kriege M, Brekelmans CT, Boetes C, et al. Differences between first and subsequent rounds of the MRISC breast cancer screening program for women with a familial or genetic predisposition. Cancer. Jun 1. 2006;106(11):2318-26. [pmid: 16615112].
187 Chung A, Saouaf R, Scharre K, et al. The impact of MRI on the treatment of DCIS. Am Surg. Sep. 2005;71(9):705-10. [pmid: 16468502].
188 Facius M, Renz DM, Neubauer H, et al. Characteristics of ductal carcinoma in situ in magnetic resonance imaging. Clin Imaging. Nov-Dec. 2007;31(6):394-400. [pmid: 17996602].
189 Rosen EL, Smith-Foley SA, DeMartini WB, et al. BI-RADS MRI enhancement characteristics of ductal carcinoma in situ. Breast J. Nov-Dec. 2007;13(6):545-50. [pmid: 17983393].
190 Riedl CC, Ponhold L, Flory D, et al. Magnetic resonance imaging of the breast improves detection of invasive cancer, preinvasive cancer, and premalignant lesions during surveillance of women at high risk for breast cancer. Clin Cancer Res. Oct 15. 2007;13(20):6144-52. [pmid: 17947480].
191 Kuhl CK, Schrading S, Bieling HB, et al. MRI for diagnosis of pure ductal carcinoma in situ: a prospective observational study. Lancet. Aug 11. 2007;370(9586):485-92. [pmid: 17693177].
192 Brem RF, Fishman M, Rapelyea JA. Detection of ductal carcinoma in situ with mammography, breast specific gamma imaging, and magnetic resonance imaging: a comparative study. Acad Radiol. Aug. 2007;14(8):945-50. [pmid: 17659240].
193 Black D, Specht M, Lee JM, et al. Detecting occult malignancy in prophylactic mastectomy: preoperative MRI versus sentinel lymph node biopsy. Ann Surg Oncol. Sep. 2007;14(9):2477-84. [pmid: 17587091].
194 Del Frate C, Borghese L, Cedolini C, et al. Role of pre-surgical breast MRI in the management of invasive breast carcinoma. Breast. Oct. 2007;16(5):469-81. [pmid: 17433681].
195 Kanemaki Y, Kurihara Y, Okamoto K, et al. Ductal carcinoma in situ: correlations between high-resolution magnetic resonance imaging and histopathology. Radiat Med. Jan. 2007;25(1):1-7. [pmid: 17225046].
196 Schouten van der Velden AP, Boetes C, Bult P, et al. The value of magnetic resonance imaging in diagnosis and size assessment of in situ and small invasive breast carcinoma. Am J Surg. Aug. 2006;192(2):172-8. [pmid: 16860625].
197 Bazzocchi M, Zuiani C, Panizza P, et al. Contrast-enhanced breast MRI in patients with suspicious microcalcifications on mammography: results of a multicenter trial. AJR Am J Roentgenol. Jun. 2006;186(6):1723-32. [pmid: 16714666].
198 Liberman L, Mason G, Morris EA, et al. Does size matter? Positive predictive value of MRI-detected breast lesions as a function of lesion size. AJR Am J Roentgenol. Feb. 2006;186(2):426-30. [pmid: 16423948].
199 Menell JH, Morris EA, Dershaw DD, et al. Determination of the presence and extent of pure ductal carcinoma in situ by mammography and magnetic resonance imaging. Breast J. Nov-Dec. 2005;11(6):382-90. [pmid: 16297080].
200 Kuhl CK, Schrading S, Leutner CC, et al. Mammography, breast ultrasound, and magnetic resonance imaging for surveillance of women at high familial risk for breast cancer. J Clin Oncol. Nov 20. 2005;23(33):8469-76. [pmid: 16293877].
201 Shiraishi A, Kurosaki Y, Maehara T, et al. Extension of ductal carcinoma in situ: histopathological association with MR imaging and mammography. Magn Reson Med Sci. Dec 31. 2003;2(4):159-63. [pmid: 16222109].
202 Groves AM, Warren RM, Godward S, et al. Characterization of pure high-grade DCIS on magnetic resonance imaging using the evolving breast MR lexicon terminology: can it be differentiated from pure invasive disease?. Magn Reson Imaging. Jul. 2005;23(6):733-8. [pmid: 16198828].
203 Mariano MN, van den Bosch MA, Daniel BL, et al. Contrast-enhanced MRI of ductal carcinoma in situ: characteristics of a new intensity-modulated parametric mapping technique correlated with histopathologic findings. J Magn Reson Imaging. Oct. 2005;22(4):520-6. [pmid: 16142701].
204 Pediconi F, Occhiato R, Venditti F, et al. Radial scars of the breast: contrast-enhanced magnetic resonance mammography appearance. Breast J. Jan-Feb. 2005;11(1):23-8. [pmid: 15647074].
205 Bluemke DA, Gatsonis CA, Chen MH, et al. Magnetic resonance imaging of the breast prior to biopsy. JAMA. Dec 8. 2004;292(22):2735-42. [pmid: 15585733].
206 Berg WA, Gutierrez L, NessAiver MS, et al. Diagnostic accuracy of mammography, clinical examination, US, and MR imaging in preoperative assessment of breast cancer. Radiology. Dec. 2004;233(3):830-49. [pmid: 15486214].
207 Morris EA, Liberman L, Ballon DJ, et al. MRI of occult breast carcinoma in a high-risk population. AJR Am J Roentgenol. Sep. 2003;181(3):619-26. [pmid: 12933450].
208 Hwang ES, Kinkel K, Esserman LJ, et al. Magnetic resonance imaging in patients diagnosed with ductal carcinoma-in-situ: value in the diagnosis of residual disease, occult invasion, and multicentricity. Ann Surg Oncol. May. 2003;10(4):381-8. [pmid: 12734086].
209 Neubauer H, Li M, Kuehne-Heid R, et al. High grade and non-high grade ductal carcinoma in situ on dynamic MR mammography: characteristic findings for signal increase and morphological pattern of enhancement. Br J Radiol. Jan. 2003;76(901):3-12. [pmid: 12595319].
210 Liberman L, Morris EA, Kim CM, et al. MR imaging findings in the contralateral breast of women with recently diagnosed breast cancer. AJR Am J Roentgenol. Feb. 2003;180(2):333-41. [pmid: 12540428].
211 Kelcz F, Furman-Haran E, Grobgeld D, et al. Clinical testing of high-spatial-resolution parametric contrast-enhanced MR imaging of the breast. AJR Am J Roentgenol. Dec. 2002;179(6):1485-92. [pmid: 12438042].
212 Tillman GF, Orel SG, Schnall MD, et al. Effect of breast magnetic resonance imaging on the clinical management of women with early-stage breast carcinoma. J Clin Oncol. Aug 15. 2002;20(16):3413-23. [pmid: 12177101].
213 Liberman L, Morris EA, Lee MJ, et al. Breast lesions detected on MR imaging: features and positive predictive value. AJR Am J Roentgenol. Jul. 2002;179(1):171-8. [pmid: 12076929].
214 Viehweg P, Lampe D, Buchmann J, et al. In situ and minimally invasive breast cancer: morphologic and kinetic features on contrast-enhanced MR imaging. MAGMA. Dec. 2000;11(3):129-37. [pmid: 11154954].
215 Esserman L, Hylton N, Yassa L, et al. Utility of magnetic resonance imaging in the management of breast cancer: evidence for improved preoperative staging. J Clin Oncol. Jan. 1999;17(1):110-9. [pmid: 10458224].
216 Orel SG, Mendonca MH, Reynolds C, et al. MR imaging of ductal carcinoma in situ. Radiology. Feb. 1997;202(2):413-20. [pmid: 9015067].
217 Boetes C, Strijk SP, Holland R, et al. False-negative MR imaging of malignant breast tumors. Eur Radiol. 1997;7(8):1231-4. [pmid: 9377507].
218 Lehman CD, Gatsonis C, Kuhl CK, et al. MRI evaluation of the contralateral breast in women with recently diagnosed breast cancer. N Engl J Med. Mar 29. 2007;356(13):1295-303. [pmid: 17392300].
219 Tiling R, Khalkhali I, Sommer H, et al. Limited value of scintimammography and contrast-enhanced MRI in the evaluation of microcalcification detected by mammography. Nucl Med Commun. Jan. 1998;19(1):55-62. [pmid: 9515547].
220 Mackinnon WB, Barry PA, Malycha PL, et al. Fine-needle biopsy specimens of benign breast lesions distinguished from invasive cancer ex vivo with proton MR spectroscopy. Radiology. Sep. 1997;204(3):661-6. [pmid: 9280241].
221 Pediconi F, Venditti F, Padula S, et al. CE-Magnetic Resonance Mammography for the evaluation of the contralateral breast in patients with diagnosed breast cancer. Radiol Med (Torino). Jul-Aug. 2005;110(1-2):61-8. [pmid: 16163140].
222 Esserman LJ, Kumar AS, Herrera AF, et al. Magnetic resonance imaging captures the biology of ductal carcinoma in situ. J Clin Oncol. Oct 1. 2006;24(28):4603-10. [pmid: 17008702].
223 Santamaria G, Velasco M, Farrus B, et al. Preoperative MRI of pure intraductal breast carcinoma--a valuable adjunct to mammography in assessing cancer extent. Breast. Apr. 2008;17(2):186-94. [pmid: 17964786].
224 Sardanelli F, Bacigalupo L, Carbonaro L, et al. What is the sensitivity of mammography and dynamic MR imaging for DCIS if the whole-breast histopathology is used as a reference standard?. Radiol Med (Torino). Apr. 2008;113(3):439-51. [pmid: 18414812].
225 Zhang Y, Fukatsu H, Naganawa S, et al. The role of contrast-enhanced MR mammography for determining candidates for breast conservation surgery. Breast Cancer. 2002;9(3):231-9. [pmid: 12185335].
226 Tan JE, Orel SG, Schnall MD, et al. Role of magnetic resonance imaging and magnetic resonance imaging--guided surgery in the evaluation of patients with early-stage breast cancer for breast conservation treatment. Am J Clin Oncol. Aug. 1999;22(4):414-8. [pmid: 10440203].
227 Schelfout K, Van Goethem M, Kersschot E, et al. Contrast-enhanced MR imaging of breast lesions and effect on treatment. Eur J Surg Oncol. Jun. 2004;30(5):501-7. [pmid: 15135477].
228 Mumtaz H, Hall-Craggs MA, Davidson T, et al. Staging of symptomatic primary breast cancer with MR imaging. AJR Am J Roentgenol. Aug. 1997;169(2):417-24. [pmid: 9242745].
229 Hollingsworth AB, Stough RG. Preoperative breast MRI for locoregional staging. J Okla State Med Assoc. Oct. 2006;99(10):505-15. [pmid: 17125104].
230 Houssami N, Ciatto S, Macaskill P, et al. Accuracy and surgical impact of magnetic resonance imaging in breast cancer staging: systematic review and meta-analysis in detection of multifocal and multicentric cancer. J Clin Oncol. Jul 1. 2008;26(19):3248-58. [pmid: 18474876].
231 Hollingsworth AB, Stough RG, O’Dell CA, et al. Breast magnetic resonance imaging for preoperative locoregional staging. Am J Surg. Sep. 2008;196(3):389-97. [pmid: 18436185].
232 Onesti JK, Mangus BE, Helmer SD, et al. Breast cancer tumor size: correlation between magnetic resonance imaging and pathology measurements. Am J Surg. Dec. 2008;196(6):844-48. discussion 9-50. [pmid: 19095098].
233 Vag T, Baltzer PA, Renz DM, et al. Diagnosis of ductal carcinoma in situ using contrast-enhanced magnetic resonance mammography compared with conventional mammography. Clin Imaging. Nov-Dec. 2008;32(6):438-42. [pmid: 19006771].
234 Houserkova D, Prasad SN, Svach I, et al. The value of dynamic contrast enhanced breast MRI in mammographically detected BI-RADS 5 microcalcifications. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub. Jun. 2008;152(1):107-15. [pmid: 18795084].
235 Raza S, Vallejo M, Chikarmane SA, et al. Pure ductal carcinoma in situ: a range of MRI features. AJR Am J Roentgenol. Sep. 2008;191(3):689-99. [pmid: 18716095].
236 Huo L, Sneige N, Hunt KK, et al. Predictors of invasion in patients with core-needle biopsy-diagnosed ductal carcinoma in situ and recommendations for a selective approach to sentinel lymph node biopsy in ductal carcinoma in situ. Cancer. Oct 15. 2006;107(8):1760-8. [pmid: 16977650].
237 Dominguez FJ, Golshan M, Black DM, et al. Sentinel node biopsy is important in mastectomy for ductal carcinoma in situ. Ann Surg Oncol. Jan. 2008;15(1):268-73. [pmid: 17891441].
238 Sakr R, Antoine M, Barranger E, et al. Value of sentinel lymph node biopsy in breast ductal carcinoma in situ upstaged to invasive carcinoma. Breast J. Jan-Feb. 2008;14(1):55-60. [pmid: 18186866].
239 Sakr R, Barranger E, Antoine M, et al. Ductal carcinoma in situ: value of sentinel lymph node biopsy. J Surg Oncol. Oct 1. 2006;94(5):426-30. [pmid: 16967457].
240 Veronesi P, Intra M, Vento AR, et al. Sentinel lymph node biopsy for localised ductal carcinoma in situ?. Breast. Dec. 2005;14(6):520-2. [pmid: 16185871].
241 Uematsu T, Yuen S, Kasami M, et al. Comparison of magnetic resonance imaging, multidetector row computed tomography, ultrasonography, and mammography for tumor extension of breast cancer. Breast Cancer Res Treat. Dec. 2008;112(3):461-74. [pmid: 18193352].
242 Katipamula R, Hoskin TL, Boughey JC, et al. Trends in mastectomy rates at the Mayo Clinic Rochester: Effect of surgical year and preoperative MRI. J Clin Oncol. 2008;26(9s). abstr 509.
243 Cox CE, Haddad F, Bass S, et al. Lymphatic mapping in the treatment of breast cancer. Oncology (Williston Park). Sep. 1998;12(9):1283-92. discussion 93-4. [pmid: 9778675].
244 Cox CE, Bass SS, Ku NN, et al. Sentinel lymphadenectomy: a safe answer to less axillary surgery?. Recent Results Cancer Res. 1998;152:170-9. [pmid: 9928556].
245 Bass SS, Lyman GH, McCann CR, et al. Lymphatic Mapping and Sentinel Lymph Node Biopsy. Breast J. Sep. 1999;5(5):288-95. [pmid: 11348304].
246 Bass SS, Dauway E, Mahatme A, et al. Lymphatic mapping with sentinel lymph node biopsy in patients with breast cancers <1 centimeter (T1A-T1B). Am Surg. Sep. 1999;65(9):857-61. discussion 61-2. [pmid: 10484089].
247 Zavotsky J, Hansen N, Brennan MB, et al. Lymph node metastasis from ductal carcinoma in situ with microinvasion. Cancer. Jun 1. 1999;85(11):2439-43. [pmid: 10357415].
248 Klauber-DeMore N, Tan LK, Liberman L, et al. Sentinel lymph node biopsy: is it indicated in patients with high-risk ductal carcinoma-in-situ and ductal carcinoma-in-situ with microinvasion?. Ann Surg Oncol. Oct. 2000;7(9):636-42. [pmid: 11034239].
249 Pendas S, Dauway E, Giuliano R, et al. Sentinel node biopsy in ductal carcinoma in situ patients. Ann Surg Oncol. Jan-Feb. 2000;7(1):15-20. [pmid: 10674443].
250 Cox CE, Nguyen K, Gray RJ, et al. Importance of lymphatic mapping in ductal carcinoma in situ (DCIS): why map DCIS. Am Surg. Jun. 2001;67(6):513-9. discussion 9-21. [pmid: 11409797].
251 Buonomo O, Granai AV, Felici A, et al. Day-surgical management of ductal carcinoma in situ (DCIS) of the breast using wide local excision with sentinel node biopsy. Tumori. May-Jun. 2002;88(3):S48-9. [pmid: 12365390].
252 Tamhane R, Dahlstrom JE, McCallum DD, et al. The clinical significance of cytokeratin-positive cells in lymph nodes at the time of mastectomy from patients with ductal carcinoma-in-situ. Ann Surg Oncol. Dec. 2002;9(10):999-1003. [pmid: 12464593].
253 Wong SL, Chao C, Edwards MJ, et al. Frequency of sentinel lymph node metastases in patients with favorable breast cancer histologic subtypes. Am J Surg. Dec. 2002;184(6):492-8. discussion 8. [pmid: 12488144].
254 Intra M, Veronesi P, Mazzarol G, et al. Axillary sentinel lymph node biopsy in patients with pure ductal carcinoma in situ of the breast. Arch Surg. Mar. 2003;138(3):309-13. [pmid: 12611580].
255 Intra M, Zurrida S, Maffini F, et al. Sentinel lymph node metastasis in microinvasive breast cancer. Ann Surg Oncol. Dec. 2003;10(10):1160-5. [pmid: 14654471].
256 Kelly TA, Kim JA, Patrick R, et al. Axillary lymph node metastases in patients with a final diagnosis of ductal carcinoma in situ. Am J Surg. Oct. 2003;186(4):368-70. [pmid: 14553852].
257 Liu CL, Yang TL, Chen BF. Sentinel lymph node mapping with emulsion of activated carbon particles in patients with pre-mastectomy diagnosis of intraductal carcinoma of the breast. J Chin Med Assoc. Jul. 2003;66(7):406-10. [pmid: 14509402].
258 Rahusen FD, Meijer S, Taets van Amerongen AH, et al. Sentinel node biopsy for nonpalpable breast tumors requires a preoperative diagnosis of invasive breast cancer. Breast J. Sep-Oct. 2003;9(5):380-4. [pmid: 12968957].
259 Farkas EA, Stolier AJ, Teng SC, et al. An argument against routine sentinel node mapping for DCIS. Am Surg. Jan. 2004;70(1):13-7. discussion 7-8. [pmid: 14964539].
260 Trisal V, Qian D, Wagman LD. Axillary recurrence in DCIs: is axillary lymphadenectomy warranted?. Am Surg. Oct. 2004;70(10):876-80. [pmid: 15529841].
261 Camp R, Feezor R, Kasraeian A, et al. Sentinel lymph node biopsy for ductal carcinoma in situ: an evolving approach at the University of Florida. Breast J. Nov-Dec. 2005;11(6):394-7. [pmid: 16297082].
262 Mittendorf EA, Arciero CA, Gutchell V, et al. Core biopsy diagnosis of ductal carcinoma in situ: an indication for sentinel lymph node biopsy. Curr Surg. Mar-Apr. 2005;62(2):253-7. [pmid: 15796952].
263 Wilkie C, White L, Dupont E, et al. An update of sentinel lymph node mapping in patients with ductal carcinoma in situ. Am J Surg. Oct. 2005;190(4):563-6. [pmid: 16164920].
264 Yen TW, Hunt KK, Ross MI, et al. Predictors of invasive breast cancer in patients with an initial diagnosis of ductal carcinoma in situ: a guide to selective use of sentinel lymph node biopsy in management of ductal carcinoma in situ. J Am Coll Surg. Apr. 2005;200(4):516-26. [pmid: 15804465].
265 Zavagno G, Carcoforo P, Marconato R, et al. Role of axillary sentinel lymph node biopsy in patients with pure ductal carcinoma in situ of the breast. BMC Cancer. Mar 11. 2005;5:28. [pmid: 15762990].
266 Fraile M, Gubern JM, Rull M, et al. Is it possible to refine the indication for sentinel node biopsy in high-risk ductal carcinoma in situ?. Nucl Med Commun. Oct. 2006;27(10):785-9. [pmid: 16969260].
267 Katz A, Gage I, Evans S, et al. Sentinel lymph node positivity of patients with ductal carcinoma in situ or microinvasive breast cancer. Am J Surg. Jun. 2006;191(6):761-6. [pmid: 16720145].
268 Leidenius M, Salmenkivi K, von Smitten K, et al. Tumour-positive sentinel node findings in patients with ductal carcinoma in situ. J Surg Oncol. Oct 1. 2006;94(5):380-4. [pmid: 16967467].
269 Mabry H, Giuliano AE, Silverstein MJ. What is the value of axillary dissection or sentinel node biopsy in patients with ductal carcinoma in situ?. Am J Surg. Oct. 2006;192(4):455-7. [pmid: 16978948].
270 Maffuz A, Barroso-Bravo S, Najera I, et al. Tumor size as predictor of microinvasion, invasion, and axillary metastasis in ductal carcinoma in situ. J Exp Clin Cancer Res. Jun. 2006;25(2):223-7. [pmid: 16918134].
271 Barros AC, Barros MA, Andrade FE, et al. Combined radioguided nonpalpable lesion localization and sentinel lymph node biopsy for early breast carcinoma. Ann Surg Oncol. Apr. 2007;14(4):1472-7. [pmid: 17225979].
272 Genta F, Zanon E, Camanni M, et al. Cost/accuracy ratio analysis in breast cancer patients undergoing ultrasound-guided fine-needle aspiration cytology, sentinel node biopsy, and frozen section of node. World J Surg. Jun. 2007;31(6):1155-63. [pmid: 17464539].
273 Gray RJ, Mulheron B, Pockaj BA, et al. The optimal management of the axillae of patients with microinvasive breast cancer in the sentinel lymph node era. Am J Surg. Dec. 2007;194(6):845-8. discussion 8-9. [pmid: 18005782].
274 Meijnen P, Oldenburg HS, Loo CE, et al. Risk of invasion and axillary lymph node metastasis in ductal carcinoma in situ diagnosed by core-needle biopsy. Br J Surg. Aug. 2007;94(8):952-6. [pmid: 17440955].
275 Moore KH, Sweeney KJ, Wilson ME, et al. Outcomes for women with ductal carcinoma-in-situ and a positive sentinel node: a multi-institutional audit. Ann Surg Oncol. Oct. 2007;14(10):2911-7. [pmid: 17597346].
276 Tan JC, McCready DR, Easson AM, et al. Role of sentinel lymph node biopsy in ductal carcinoma-in-situ treated by mastectomy. Ann Surg Oncol. Feb. 2007;14(2):638-45. [pmid: 17103256].
277 Zavagno G, Belardinelli V, Marconato R, et al. Sentinel lymph node metastasis from mammary ductal carcinoma in situ with microinvasion. Breast. Apr. 2007;16(2):146-51. [pmid: 17046258].
278 Intra M, Rotmensz N, Veronesi P, et al. Sentinel node biopsy is not a standard procedure in ductal carcinoma in situ of the breast: the experience of the European institute of oncology on 854 patients in 10 years. Ann Surg. Feb. 2008;247(2):315-9. [pmid: 18216539].
279 Murphy CD, Jones JL, Javid SH, et al. Do sentinel node micrometastases predict recurrence risk in ductal carcinoma in situ and ductal carcinoma in situ with microinvasion. Am J Surg. 2008. Aug. 28.
280 Polom K, Murawa D, Wasiewicz J, et al. The role of sentinel node biopsy in ductal carcinoma in situ of the breast. Eur J Surg Oncol. Jan. 2009;35(1):43-7. [pmid: 18723312].
281 Tunon-de-Lara C, Giard S, Buttarelli M, et al. Sentinel node procedure is warranted in ductal carcinoma in situ with high risk of occult invasive carcinoma and microinvasive carcinoma treated by mastectomy. Breast J. Mar-Apr. 2008;14(2):135-40. [pmid: 18315691].
282 van la Parra RF, Ernst MF, Barneveld PC, et al. The value of sentinel lymph node biopsy in ductal carcinoma in situ (DCIS) and DCIS with microinvasion of the breast. Eur J Surg Oncol. Jun. 2008;34(6):631-5. [pmid: 17851019].
283 Yi M, Krishnamurthy S, Kuerer HM, et al. Role of primary tumor characteristics in predicting positive sentinel lymph nodes in patients with ductal carcinoma in situ or microinvasive breast cancer. Am J Surg. Jul. 2008;196(1):81-7. [pmid: 18436181].
284 Sakr R, Bezu C, Raoust I, et al. The sentinel lymph node procedure for patients with preoperative diagnosis of ductal carcinoma in situ: risk factors for unsuspected invasive disease and for metastatic sentinel lymph nodes. Int J Clin Pract. Nov. 2008;62(11):1730-5. [pmid: 19143859].
285 Guth AA, Mercado C, Roses DF, et al. Microinvasive breast cancer and the role of sentinel node biopsy: an institutional experience and review of the literature. Breast J. Jul-Aug. 2008;14(4):335-9. [pmid: 18537917].
286 Takacs T, Paszt A, Szentpali K, et al. Importance of Sentinel Lymph Node Biopsy in Surgical Therapy of in situ Breast Cancer. Pathol Oncol Res. 2008. Nov. 21.
287 El-Tamer M, Chun J, Gill M, et al. Incidence and clinical significance of lymph node metastasis detected by cytokeratin immunohistochemical staining in ductal carcinoma in situ. Ann Surg Oncol. Mar. 2005;12(3):254-9. [pmid: 15827818].
288 Goyal A, Douglas-Jones A, Monypenny I, et al. Is there a role of sentinel lymph node biopsy in ductal carcinoma in situ?: analysis of 587 cases. Breast Cancer Res Treat. Aug. 2006;98(3):311-4. [pmid: 16552627].
289 Ansari B, Ogston SA, Purdie CA, et al. Meta-analysis of sentinel node biopsy in ductal carcinoma in situ of the breast. Br J Surg. May. 2008;95(5):547-54. [pmid: 18386775].
290 Tan MP. Surmounting the challenges of sentinel lymph node biopsy for breast cancer in non-tertiary centres and community-based practices. ANZ J Surg. May. 2006;76(5):306-9. [pmid: 16768687].
291 Wong SL, Edwards MJ, Chao C, et al. The effect of prior breast biopsy method and concurrent definitive breast procedure on success and accuracy of sentinel lymph node biopsy. Ann Surg Oncol. Apr. 2002;9(3):272-7. [pmid: 11923134].
292 Haigh PI, Hansen NM, Qi K, et al. Biopsy method and excision volume do not affect success rate of subsequent sentinel lymph node dissection in breast cancer. Ann Surg Oncol. Jan-Feb. 2000;7(1):21-7. [pmid: 10674444].
293 Langer I, Guller U, Berclaz G, et al. Morbidity of sentinel lymph node biopsy (SLN) alone versus SLN and completion axillary lymph node dissection after breast cancer surgery: a prospective Swiss multicenter study on 659 patients. Ann Surg. Mar. 2007;245(3):452-61. [pmid: 17435553].
294 Wilke LG, McCall LM, Posther KE, et al. Surgical complications associated with sentinel lymph node biopsy: results from a prospective international cooperative group trial. Ann Surg Oncol. Apr. 2006;13(4):491-500. [pmid: 16514477].
295 Fisher ER, Dignam J, Tan-Chiu E, et al. Pathologic findings from the National Surgical Adjuvant Breast Project (NSABP) eight-year update of Protocol B-17: intraductal carcinoma. Cancer. Aug 1. 1999;86(3):429-38. [pmid: 10430251].
296 Smith BD, Haffty BG, Buchholz TA, et al. Effectiveness of radiation therapy in older women with ductal carcinoma in situ. J Natl Cancer Inst. Sep 20. 2006;98(18):1302-10. [pmid: 16985249].
297 Solin LJ, Fourquet A, Vicini FA, et al. Long-term outcome after breast-conservation treatment with radiation for mammographically detected ductal carcinoma in situ of the breast. Cancer. Mar 15. 2005;103(6):1137-46. [pmid: 15674853].
298 Vicini FA, Kestin LL, Goldstein NS, et al. Impact of young age on outcome in patients with ductal carcinoma-in-situ treated with breast-conserving therapy. J Clin Oncol. Jan. 2000;18(2):296-306. [pmid: 10637243].
299 Fowble BL, Solin LJ, Schultz DJ, et al. Ten year results of conservative surgery and irradiation for stage I and II breast cancer. Int J Radiat Oncol Biol Phys. Jul. 1991;21(2):269-77. [pmid: 1648040].
300 Lara JF, Young SM, Velilla RE, et al. The relevance of occult axillary micrometastasis in ductal carcinoma in situ: a clinicopathologic study with long-term follow-up. Cancer. Nov 15. 2003;98(10):2105-13. [pmid: 14601079].
301 Ottesen GL, Graversen HP, Blichert-Toft M, et al. Ductal carcinoma in situ of the female breast. Short-term results of a prospective nationwide study. The Danish Breast Cancer Cooperative Group. Am J Surg Pathol. Dec. 1992;16(12):1183-96. [pmid: 1334379].
302 Habel LA, Moe RE, Daling JR, et al. Risk of contralateral breast cancer among women with carcinoma in situ of the breast. Ann Surg. Jan. 1997;225(1):69-75. [pmid: 8998122].
303 Amichetti M, Caffo O, Richetti A, et al. Ten-year results of treatment of ductal carcinoma in situ (DCIS) of the breast with conservative surgery and radiotherapy. Eur J Cancer. Sep. 1997;33(10):1559-65. [pmid: 9389915].
304 Gao X, Fisher SG, Emami B. Risk of second primary cancer in the contralateral breast in women treated for early-stage breast cancer: a population-based study. Int J Radiat Oncol Biol Phys. Jul 15. 2003;56(4):1038-45. [pmid: 12829139].
305 Solin LJ, Fourquet A, McCormick B, et al. Salvage treatment for local recurrence following breast-conserving surgery and definitive irradiation for ductal carcinoma in situ (intraductal carcinoma) of the breast. Int J Radiat Oncol Biol Phys. Aug 30. 1994;30(1):3-9. [pmid: 8083125].
306 Solin LJ, Kurtz J, Fourquet A, et al. Fifteen-year results of breast-conserving surgery and definitive breast irradiation for the treatment of ductal carcinoma in situ of the breast. J Clin Oncol. Mar. 1996;14(3):754-63. [pmid: 8622021].
307 Vargas C, Kestin L, Go N, et al. Factors associated with local recurrence and cause-specific survival in patients with ductal carcinoma in situ of the breast treated with breast-conserving therapy or mastectomy. Int J Radiat Oncol Biol Phys. Dec 1. 2005;63(5):1514-21. [pmid: 16005576].
308 Chuwa EW, Tan VH, Tan PH, et al. Treatment for ductal carcinoma in situ in an Asian population: outcome and prognostic factors. ANZ J Surg. Jan-Feb. 2008;78(1-2):42-8. [pmid: 18199204].
309 Ben-David MA, Sturtz DE, Griffith KA, et al. Long-term results of conservative surgery and radiotherapy for ductal carcinoma in situ using lung density correction: the University of Michigan experience. Breast J. Jul-Aug. 2007;13(4):392-400. [pmid: 17593044].
310 Meijnen P, Oldenburg HS, Peterse JL, et al. Clinical outcome after selective treatment of patients diagnosed with ductal carcinoma in situ of the breast. Ann Surg Oncol. Jan. 2008;15(1):235-43. [pmid: 17987342].
311 Sahoo S, Recant WM, Jaskowiak N, et al. Defining negative margins in DCIS patients treated with breast conservation therapy: The University of Chicago experience. Breast J. Jul-Aug. 2005;11(4):242-7. [pmid: 15982389].
312 Omlin A, Amichetti M, Azria D, et al. Boost radiotherapy in young women with ductal carcinoma in situ: a multicentre, retrospective study of the Rare Cancer Network. Lancet Oncol. Aug. 2006;7(8):652-6. [pmid: 16887482].
313 Wilson GR, Cramer A, Welman A, et al. Activated c-SRC in ductal carcinoma in situ correlates with high tumour grade, high proliferation and HER2 positivity. Br J Cancer. Nov 20. 2006;95(10):1410-4. [pmid: 17060931].
314 Cutuli B, Cohen-Solal-Le Nir C, De Lafontan B, et al. Ductal carcinoma in situ of the breast results of conservative and radical treatments in 716 patients. Eur J Cancer. Dec. 2001;37(18):2365-72. [pmid: 11720829].
315 Schouten van der Velden AP, van Vugt R, Van Dijck JA, et al. Local recurrences after different treatment strategies for ductal carcinoma in situ of the breast: a population-based study in the East Netherlands. Int J Radiat Oncol Biol Phys. Nov 1. 2007;69(3):703-10. [pmid: 17544591].
316 Warren JL, Weaver DL, Bocklage T, et al. The frequency of ipsilateral second tumors after breast-conserving surgery for DCIS: a population based analysis. Cancer. Nov 1. 2005;104(9):1840-8. [pmid: 16136599].
317 Boland GP, Chan KC, Knox WF, et al. Value of the Van Nuys Prognostic Index in prediction of recurrence of ductal carcinoma in situ after breast-conserving surgery. Br J Surg. Apr. 2003;90(4):426-32. [pmid: 12673743].
318 Vicini FA, Kestin LL, Goldstein NS, et al. Relationship between excision volume, margin status, and tumor size with the development of local recurrence in patients with ductal carcinoma-in-situ treated with breast-conserving therapy. J Surg Oncol. Apr. 2001;76(4):245-54. [pmid: 11320515].
319 Cutuli B, Cohen-Solal-le Nir C, de Lafontan B, et al. Breast-conserving therapy for ductal carcinoma in situ of the breast: the French Cancer Centers’ experience. Int J Radiat Oncol Biol Phys. Jul 15. 2002;53(4):868-79. [pmid: 12095552].
320 MacDonald HR, Silverstein MJ, Mabry H, et al. Local control in ductal carcinoma in situ treated by excision alone: incremental benefit of larger margins. Am J Surg. Oct. 2005;190(4):521-5. [pmid: 16164913].
321 Rakovitch E, Pignol JP, Hanna W, et al. Significance of multifocality in ductal carcinoma in situ: outcomes of women treated with breast-conserving therapy. J Clin Oncol. Dec 10. 2007;25(35):5591-6. [pmid: 17984188].
322 Kerlikowske K, Molinaro A, Cha I, et al. Characteristics associated with recurrence among women with ductal carcinoma in situ treated by lumpectomy. J Natl Cancer Inst. Nov 19. 2003;95(22):1692-702. [pmid: 14625260].
323 Bijker N, Meijnen P, Peterse JL, et al. Breast-conserving treatment with or without radiotherapy in ductal carcinoma-in-situ: ten-year results of European Organisation for Research and Treatment of Cancer randomized phase III trial 10853--a study by the EORTC Breast Cancer Cooperative Group and EORTC Radiotherapy Group. J Clin Oncol. Jul 20. 2006;24(21):3381-7. [pmid: 16801628].
324 Fisher B, Land S, Mamounas E, et al. Prevention of invasive breast cancer in women with ductal carcinoma in situ: an update of the national surgical adjuvant breast and bowel project experience. Semin Oncol. Aug. 2001;28(4):400-18. [pmid: 11498833].
325 Solin LJ, Yeh IT, Kurtz J, et al. Ductal carcinoma in situ (intraductal carcinoma) of the breast treated with breast-conserving surgery and definitive irradiation. Correlation of pathologic parameters with outcome of treatment. Cancer. Apr 15. 1993;71(8):2532-42. [pmid: 8384070].
326 Tunon-de-Lara C, de-Mascarel I, Mac-Grogan G, et al. Analysis of 676 cases of ductal carcinoma in situ of the breast from 1971 to 1995: diagnosis and treatment--the experience of one institute. Am J Clin Oncol. Dec. 2001;24(6):531-6. [pmid: 11801749].
327 Fish EB, Chapman JA, Miller NA, et al. Assessment of treatment for patients with primary ductal carcinoma in situ in the breast. Ann Surg Oncol. Dec. 1998;5(8):724-32. [pmid: 9869520].
328 Miller NA, Chapman JA, Fish EB, et al. In situ duct carcinoma of the breast: clinical and histopathologic factors and association with recurrent carcinoma. Breast J. Sep-Oct. 2001;7(5):292-302. [pmid: 11906438].
329 Chan KC, Knox WF, Sinha G, et al. Extent of excision margin width required in breast conserving surgery for ductal carcinoma in situ. Cancer. Jan 1. 2001;91(1):9-16. [pmid: 11148554].
330 de Roos MA, de Bock GH, de Vries J, et al. p53 overexpression is a predictor of local recurrence after treatment for both in situ and invasive ductal carcinoma of the breast. J Surg Res. Jun 1. 2007;140(1):109-14. [pmid: 17291532].
331 Holmberg L, Garmo H, Granstrand B, et al. Absolute risk reductions for local recurrence after postoperative radiotherapy after sector resection for ductal carcinoma in situ of the breast. J Clin Oncol. Mar 10. 2008;26(8):1247-52. [pmid: 18250350].
332 Cataliotti L, Distante V, Ciatto S, et al. Intraductal breast cancer: review of 183 consecutive cases. Eur J Cancer. 1992;28A(4–5):917-20. [pmid: 1326310].
333 Habel LA, Daling JR, Newcomb PA, et al. Risk of recurrence after ductal carcinoma in situ of the breast. Cancer Epidemiol Biomarkers Prev. Aug. 1998;7(8):689-96. [pmid: 9718221].
334 Bonnier P, Body G, Bessenay F, et al. Prognostic factors in ductal carcinoma in situ of the breast: results of a retrospective study of 575 cases. The Association for Research in Oncologic Gynecology. Eur J Obstet Gynecol Reprod Biol. May. 1999;84(1):27-35. [pmid: 10413223].
335 Van Zee KJ, Liberman L, Samli B, et al. Long term follow-up of women with ductal carcinoma in situ treated with breast-conserving surgery: the effect of age. Cancer. Nov 1. 1999;86(9):1757-67. [pmid: 10547549].
336 Ringberg A, Idvall I, Ferno M, et al. Ipsilateral local recurrence in relation to therapy and morphological characteristics in patients with ductal carcinoma in situ of the breast. Eur J Surg Oncol. Aug. 2000;26(5):444-51. [pmid: 11016463].
337 Ottesen GL, Graversen HP, Blichert-Toft M, et al. Carcinoma in situ of the female breast. 10 year follow-up results of a prospective nationwide study. Breast Cancer Res Treat. Aug. 2000;62(3):197-210. [pmid: 11072784].
338 Warnberg F, Bergh J, Zack M, et al. Risk factors for subsequent invasive breast cancer and breast cancer death after ductal carcinoma in situ: a population-based case-control study in Sweden. Cancer Epidemiol Biomarkers Prev. May. 2001;10(5):495-9. [pmid: 11352860].
339 Neuschatz AC, DiPetrillo T, Safaii H, et al. Margin width as a determinant of local control with and without radiation therapy for ductal carcinoma in situ (DCIS) of the breast. Int J Cancer. 2001;96(Suppl):97-104. [pmid: 11992392].
340 Douglas-Jones AG, Logan J, Morgan JM, et al. Effect of margins of excision on recurrence after local excision of ductal carcinoma in situ of the breast. J Clin Pathol. Aug. 2002;55(8):581-6. [pmid: 12147650].
341 Nakamura S, Woo C, Silberman H, et al. Breast-conserving therapy for ductal carcinoma in situ: a 20-year experience with excision plus radiation therapy. Am J Surg. Nov. 2002;184(5):403-9. [pmid: 12433602].
342 Roka S, Rudas M, Taucher S, et al. High nuclear grade and negative estrogen receptor are significant risk factors for recurrence in DCIS. Eur J Surg Oncol. Apr. 2004;30(3):243-7. [pmid: 15028303].
343 Cornfield DB, Palazzo JP, Schwartz GF, et al. The prognostic significance of multiple morphologic features and biologic markers in ductal carcinoma in situ of the breast: a study of a large cohort of patients treated with surgery alone. Cancer. Jun 1. 2004;100(11):2317-27. [pmid: 15160334].
344 de Roos MA, de Bock GH, Baas PC, et al. Compliance with guidelines is related to better local recurrence-free survival in ductal carcinoma in situ. Br J Cancer. Nov 14. 2005;93(10):1122-7. [pmid: 16234825].
345 Adepoju LJ, Symmans WF, Babiera GV, et al. Impact of concurrent proliferative high-risk lesions on the risk of ipsilateral breast carcinoma recurrence and contralateral breast carcinoma development in patients with ductal carcinoma in situ treated with breast-conserving therapy. Cancer. Jan 1. 2006;106(1):42-50. [pmid: 16333852].
346 Wong JS, Kaelin CM, Troyan SL, et al. Prospective study of wide excision alone for ductal carcinoma in situ of the breast. J Clin Oncol. Mar 1. 2006;24(7):1031-6. [pmid: 16461781].
347 Li CI, Malone KE, Saltzman BS, et al. Risk of invasive breast carcinoma among women diagnosed with ductal carcinoma in situ and lobular carcinoma in situ, 1988–2001. Cancer. May 15. 2006;106(10):2104-12. [pmid: 16604564].
348 Carlson GW, Page A, Johnson E, et al. Local recurrence of ductal carcinoma in situ after skin-sparing mastectomy. J Am Coll Surg. May. 2007;204(5):1074-8. discussion 8-80. [pmid: 17481544].
349 Asjoe FT, Altintas S, Colpaert C, et al. The value of the Van Nuys Prognostic Index in ductal carcinoma in situ of the breast: a retrospective analysis. Breast J. Jul-Aug. 2007;13(4):359-67. [pmid: 17593040].
350 Di Saverio S, Catena F, Santini D, et al. 259 Patients with DCIS of the breast applying USC/Van Nuys prognostic index: a retrospective review with long term follow up. Breast Cancer Res Treat. Jun. 2008;109(3):405-16. [pmid: 17687650].
351 Dawood S, Broglio K, Gonzalez-Angulo AM, et al. Development of new cancers in patients with DCIS: the M.D. Anderson experience. Ann Surg Oncol. Jan. 2008;15(1):244-9. [pmid: 18043978].
352 Gilleard O, Goodman A, Cooper M, et al. The significance of the Van Nuys prognostic index in the management of ductal carcinoma in situ. World Journal of Surgical Oncology. 2008;6:61. [pmid: 18564426].
353 Silverstein MJ, Barth A, Poller DN, et al. Ten-year results comparing mastectomy to excision and radiation therapy for ductal carcinoma in situ of the breast. Eur J Cancer. 1995;31A(9):1425-7. [pmid: 7577065].
354 Bellamy CO, McDonald C, Salter DM, et al. Noninvasive ductal carcinoma of the breast: the relevance of histologic categorization. Hum Pathol. Jan. 1993;24(1):16-23. [pmid: 8380275].
355 Badve S, A’Hern RP, Ward AM, et al. Prediction of local recurrence of ductal carcinoma in situ of the breast using five histological classifications: a comparative study with long follow-up. Hum Pathol. Sep. 1998;29(9):915-23. [pmid: 9744307].
356 Warnberg F, Nordgren H, Bergh J, et al. Ductal carcinoma in situ of the breast from a population-defined cohort: an evaluation of new histopathological classification systems. Eur J Cancer. May. 1999;35(5):714-20. [pmid: 10505030].
357 Bijker N, Peterse JL, Duchateau L, et al. Risk factors for recurrence and metastasis after breast-conserving therapy for ductal carcinoma-in-situ: analysis of European Organization for Research and Treatment of Cancer Trial 10853. J Clin Oncol. Apr 15. 2001;19(8):2263-71. [pmid: 11304780].
358 Stallard S, Hole DA, Purushotham AD, et al. Ductal carcinoma in situ of the breast -- among factors predicting for recurrence, distance from the nipple is important. Eur J Surg Oncol. Jun. 2001;27(4):373-7. [pmid: 11417983].
359 Jhingran A, Kim JS, Buchholz TA, et al. Age as a predictor of outcome for women with DCIS treated with breast-conserving surgery and radiation: The University of Texas M. D. Anderson Cancer Center experience. Int J Radiat Oncol Biol Phys. Nov 1. 2002;54(3):804-9. [pmid: 12377332].
360 Rodrigues N, Carter D, Dillon D, et al. Correlation of clinical and pathologic features with outcome in patients with ductal carcinoma in situ of the breast treated with breast-conserving surgery and radiotherapy. Int J Radiat Oncol Biol Phys. Dec 1. 2002;54(5):1331-5. [pmid: 12459354].
361 Idvall I, Anderson H, Ringberg A, et al. Are cellular polarisation and mitotic frequency prognostic factors for local recurrence in patients with ductal carcinoma in situ of the breast?. Eur J Cancer. Aug. 2003;39(12):1704-10. [pmid: 12888365].
362 Millis RR, Pinder SE, Ryder K, et al. Grade of recurrent in situ and invasive carcinoma following treatment of pure ductal carcinoma in situ of the breast. Br J Cancer. Apr 19. 2004;90(8):1538-42. [pmid: 15083182].
363 Barnes NL, Boland GP, Davenport A, et al. Relationship between hormone receptor status and tumour size, grade and comedo necrosis in ductal carcinoma in situ. Br J Surg. Apr. 2005;92(4):429-34. [pmid: 15736216].
364 Innos K, Horn-Ross PL. Risk of second primary breast cancers among women with ductal carcinoma in situ of the breast. Breast Cancer Research & Treatment. Oct. 2008;111(3):531-40. [pmid: 17978879].
365 Silverstein MJ, Cohlan BF, Gierson ED, et al. Duct carcinoma in situ: 227 cases without microinvasion. Eur J Cancer. 1992;28(2–3):630-4. [pmid: 1317201].
366 Silverstein MJ, Waisman JR, Gierson ED, et al. Radiation therapy for intraductal carcinoma. Is it an equal alternative?. Arch Surg. Apr. 1991;126(4):424-8. [pmid: 1848972].
367 Cox CE, Hyacinthe M, Gonzalez RJ, et al. Cytologic evaluation of lumpectomy margins in patients with ductal carcinoma in situ: clinical outcome. Ann Surg Oncol. Dec. 1997;4(8):644-9. [pmid: 9416412].
368 Mirza NQ, Vlastos G, Meric F, et al. Ductal carcinoma-in-situ: long-term results of breast-conserving therapy. Ann Surg Oncol. Oct. 2000;7(9):656-64. [pmid: 11034242].
369 Warneke J, Grossklaus D, Davis J, et al. Influence of local treatment on the recurrence rate of ductal carcinoma in situ. J Am Coll Surg. Jun. 1995;180(6):683-8. [pmid: 7773481].
370 Goldstein NS, Kestin L, Vicini F. Intraductal carcinoma of the breast: pathologic features associated with local recurrence in patients treated with breast-conserving therapy. Am J Surg Pathol. Aug. 2000;24(8):1058-67. [pmid: 10935646].
371 Silverstein MJ. The University of Southern California/Van Nuys prognostic index for ductal carcinoma in situ of the breast. Am J Surg. Oct. 2003;186(4):337-43. [pmid: 14553846].
372 Silverstein MJ, Poller DN, Waisman JR, et al. Prognostic classification of breast ductal carcinoma-in-situ. Lancet. May 6. 1995;345(8958):1154-7. [pmid: 7723550].
373 Silverstein MJ, Lagios MD, Craig PH, et al. A prognostic index for ductal carcinoma in situ of the breast. Cancer. Jun 1. 1996;77(11):2267-74. [pmid: 8635094].
374 Holland PA, Gandhi A, Knox WF, et al. The importance of complete excision in the prevention of local recurrence of ductal carcinoma in situ. Br J Cancer. 1998;77(1):110-4. [pmid: 9459154].
375 Kestin LL, Goldstein NS, Martinez AA, et al. Mammographically detected ductal carcinoma in situ treated with conservative surgery with or without radiation therapy: patterns of failure and 10-year results. Ann Surg. Feb. 2000;231(2):235-45. [pmid: 10674616].
376 Smith GL, Smith BD, Haffty BG. Rationalization and regionalization of treatment for ductal carcinoma in situ of the breast. Int J Radiat Oncol Biol Phys. Aug 1. 2006;65(5):1397-403. [pmid: 16750316].
377 MacAusland SG, Hepel JT, Chong FK, et al. An attempt to independently verify the utility of the Van Nuys Prognostic Index for ductal carcinoma in situ. Cancer. Dec 15. 2007;110(12):2648-53. [pmid: 17960606].
378 de Mascarel I, Bonichon F, MacGrogan G, et al. Application of the van nuys prognostic index in a retrospective series of 367 ductal carcinomas in situ of the breast examined by serial macroscopic sectioning: practical considerations. Breast Cancer Res Treat. May. 2000;61(2):151-9. [pmid: 10942101].
379 Ringberg A, Anagnostaki L, Anderson H, et al. Cell biological factors in ductal carcinoma in situ (DCIS) of the breast-relationship to ipsilateral local recurrence and histopathological characteristics. Eur J Cancer. Aug. 2001;37(12):1514-22. [pmid: 11506959].
380 Kepple J, Henry-Tillman RS, Klimberg VS, et al. The receptor expression pattern in ductal carcinoma in situ predicts recurrence. Am J Surg. Jul. 2006;192(1):68-71. [pmid: 16769278].
381 Provenzano E, Hopper JL, Giles GG, et al. Biological markers that predict clinical recurrence in ductal carcinoma in situ of the breast. Eur J Cancer. Mar. 2003;39(5):622-30. [pmid: 12628841].
382 Jiveliouk I, Corn B, Inbar M, et al. Ductal carcinoma in situ of the breast in Israeli women treated by breast-conserving surgery followed by radiation therapy. Oncology. 2009;76(1):30-5. [pmid: 19033713].
383 Bijker N, Peterse JL, Duchateau L, et al. Histological type and marker expression of the primary tumour compared with its local recurrence after breast-conserving therapy for ductal carcinoma in situ. Br J Cancer. Feb. 2001;84(4):539-44. [pmid: 11207051].
384 Fisher ER, Leeming R, Anderson S, et al. Conservative management of intraductal carcinoma (DCIS) of the breast. Collaborating NSABP investigators. J Surg Oncol. Jul. 1991;47(3):139-47. [pmid: 1649353].
385 Warnberg F, Amini RM, Goldman M, et al. Quality aspects of the tissue microarray technique in a population-based cohort with ductal carcinoma in situ of the breast. Histopathology. Dec. 2008;53(6):642-9. [pmid: 19076680].
386 Barnes NL, Khavari S, Boland GP, et al. Absence of HER4 expression predicts recurrence of ductal carcinoma in situ of the breast. Clin Cancer Res. Mar 15. 2005;11(6):2163-8. [pmid: 15788662].
387 Kestin LL, Goldstein NS, Lacerna MD, et al. Factors associated with local recurrence of mammographically detected ductal carcinoma in situ in patients given breast-conserving therapy. Cancer. Feb 1. 2000;88(3):596-607. [pmid: 10649253].
388 Rudloff U, Brogi E, Brockway JP, et al. Concurrent lobular neoplasia increases the risk of ipsilateral breast cancer recurrence in patients with ductal carcinoma in situ treated with breast-conserving therapy. Cancer. 2009. Jan. 23.
389 Joslyn SA. Ductal carcinoma in situ: trends in geographic, temporal, and demographic patterns of care and survival. Breast J. Jan-Feb. 2006;12(1):20-7. [pmid: 16409583].
390 Deshpande AD, Jeffe DB, Gnerlich J, et al. Racial disparities in breast cancer survival: an analysis by age and stage. J Surg Res. May 1. 2009;153(1):105-13. [pmid: 19084242].
391 Habel LA, Dignam JJ, Land SR, et al. Mammographic density and breast cancer after ductal carcinoma in situ. J Natl Cancer Inst. Oct 6. 2004;96(19):1467-72. [pmid: 15467036].
392 Hwang ES, Miglioretti DL, Ballard-Barbash R, et al. Association between breast density and subsequent breast cancer following treatment for ductal carcinoma in situ. Cancer Epidemiol Biomarkers Prev. Dec. 2007;16(12):2587-93. [pmid: 18086762].
393 Schouten van der Velden AP, Peeters PH, Koot VC, et al. Local recurrences after conservative treatment of ductal carcinoma-in-situ of the breast without radiotherapy: the effect of age. Ann Surg Oncol. Jul. 2006;13(7):990-8. [pmid: 16788762].
394 Fowble B, Hanlon AL, Fein DA, et al. Results of conservative surgery and radiation for mammographically detected ductal carcinoma in situ (DCIS). Int J Radiat Oncol Biol Phys. Jul 15. 1997;38(5):949-57. [pmid: 9276359].
395 Szelei-Stevens KA, Kuske RR, Yantsos VA, et al. The influence of young age and positive family history of breast cancer on the prognosis of ductal carcinoma in situ treated by excision with or without radiation therapy or by mastectomy. Int J Radiat Oncol Biol Phys. Nov 1. 2000;48(4):943-9. [pmid: 11072149].
396 Macdonald HR, Silverstein MJ, Lee LA, et al. Margin width as the sole determinant of local recurrence after breast conservation in patients with ductal carcinoma in situ of the breast. Am J Surg. Oct. 2006;192(4):420-2. [pmid: 16978941].
397 NSABP B-39, RTOG 0413: A Randomized Phase III Study of conventional whole breast irradiation versus partial breast irradiation for women with stage 0, I, or II breast cancer. Clin Adv Hematol Oncol. Oct. 2006;4(10):719-21. [pmid: 17111558].
398 Fisher B, Costantino J, Redmond C, et al. Lumpectomy compared with lumpectomy and radiation therapy for the treatment of intraductal breast cancer. N Engl J Med. Jun 3. 1993;328(22):1581-6. [pmid: 8292119].
399 Julian TB, Land SR, Fourchotte V, et al. Is sentinel node biopsy necessary in conservatively treated DCIS?. Ann Surg Oncol. Aug. 2007;14(8):2202-8. [pmid: 17534687].
400 Houghton J, George WD, Cuzick J, et al. Radiotherapy and tamoxifen in women with completely excised ductal carcinoma in situ of the breast in the UK, Australia, and New Zealand: randomised controlled trial. Lancet. Jul 12. 2003;362(9378):95-102. [pmid: 12867108].
401 Fisher B, Dignam J, Wolmark N, et al. Tamoxifen in treatment of intraductal breast cancer: National Surgical Adjuvant Breast and Bowel Project B-24 randomised controlled trial. Lancet. Jun 12. 1999;353(9169):1993-2000. [pmid: 10376613].
402 Silverstein MJ, Buchanan C. Ductal carcinoma in situ: USC/Van Nuys Prognostic Index and the impact of margin status. Breast. Dec. 2003;12(6):457-71. [pmid: 14659122].
403 McCormack VA, dos Santos Silva I. Breast density and parenchymal patterns as markers of breast cancer risk: a meta-analysis. Cancer Epidemiol Biomarkers Prev. Jun. 2006;15(6):1159-69. [pmid: 16775176].
404 Sun CL, Yuan JM, Koh WP, et al. Green tea, black tea and breast cancer risk: a meta-analysis of epidemiological studies. Carcinogenesis. Jul. 2006;27(7):1310-5. [pmid: 16311246].
405 Seely D, Mills EJ, Wu P, et al. The effects of green tea consumption on incidence of breast cancer and recurrence of breast cancer: a systematic review and meta-analysis. Integr Cancer Ther. Jun. 2005;4(2):144-55. [pmid: 15911927].
406 Trock BJ, Hilakivi-Clarke L, Clarke R. Meta-analysis of soy intake and breast cancer risk. J Natl Cancer Inst. Apr 5. 2006;98(7):459-71. [pmid: 16595782].
407 Qin LQ, Xu JY, Wang PY, et al. Soyfood intake in the prevention of breast cancer risk in women: a meta-analysis of observational epidemiological studies. J Nutr Sci Vitaminol (Tokyo). Dec. 2006;52(6):428-36. [pmid: 17330506].
408 Vogel VG. Recent results from clinical trials using SERMs to reduce the risk of breast cancer. Ann N Y Acad Sci. Nov. 2006;1089:127-42. [pmid: 17261762].