# Executive Summary

## Introduction

Ductal carcinoma in situ (DCIS) is noninvasive breast cancer that encompasses a wide spectrum of diseases ranging from low-grade lesions that are not life threatening to high-grade lesions that may harbor foci of invasive breast cancer. DCIS is characterized histologically by the proliferation of malignant epithelial cells that are bounded by the basement membrane of the breast ducts. DCIS has been classified according to architectural pattern (solid, cribriform, papillary, and micropapillary), tumor grade (high, intermediate, and low grade), and the presence or absence of comedo histology. Prior to the advent of widespread screening mammography, DCIS was usually diagnosed by surgical removal of a suspicious breast mass. DCIS was rarely diagnosed before 1980, but currently about 25 percent of breast cancers diagnosed in the United States are DCIS.

## Methods

Studies were sought from a wide variety of sources, including MEDLINE^®^ via PubMed^®^, Scirus, Cochrane databases, websites of the Sloane Project and of the International Breast Cancer Screening Network (IBSN), and manual searches of reference lists from systematic reviews and consensus conferences. We searched the database of the registered clinical trials www.clinicaltrials.gov to identity ongoing research relevant for question 5. We updated our search in February 2009 and include articles published through January 31, 2009.

We reviewed abstracts to confirm eligible target populations of female adults to examine incidence of DCIS and adult female patients with treated or untreated DCIS.

## Results

The incidence of DCIS has risen from 1.87 per 100,000 women from 1973–1975 to 32.5 per 100,000 in 2004. The incidence of DCIS increased in all age categories with the greatest rise among those older than 50 years of age. Age adjusted DCIS incidence rates increased 7.2-fold from 1980 to 2004. The annual incidence among those older than 50 years of age demonstrated an exponential increase from five per 100,000 in 1980 to 59–77 per 100,000 in 2004.

While other countries have also observed increases in DCIS in recent years, no country has experienced as steep an increase in DCIS as the United States. The increase in DCIS has not, however, been uniform across histologic types. Comedo histology is associated with a particularly high risk of recurrence and has been stable over recent years. In contrast, low-grade DCIS, generally considered to be less likely to recur or develop into invasive breast cancer, has accounted for the majority of the recent increase.

Many studies point to increased use of mammography as the likely explanation for the increased incidence, but the increased incidence cannot be entirely explained by an increase in screening. Cumulative incidence per 1,000 mammograms increased from 0.9 in January 1997 to 1.7 in December 2003. We assessed the impact of screening by comparing patterns of incidence using two different definitions: DCIS incidence per 100,000 female population and per 1,000 screened women. Incidence of DCIS in the United States increased over time according to both definitions. Older women had higher incidence according to both defintions. Proportional changes, when compared across the studies, tend to be larger for incidence per 100,000. The data revealed greater inceases over time in incidence per 100,000 population than per 1,000 screened.

Several risk factors are associated with DCIS. Less educated women (<high school) had greater cumulative incidences of DCIS than women with higher education. Registry data consistently show that the odds of DCIS increase until age 65–69 and then decline. The odds of DCIS were 3.7 times greater among those older versus younger than 60 years. Age at menarche was not associated with DCIS. Age adjusted incidence of DCIS was the highest among Caucasian women followed by African American and Asian-Pacific Islanders.

Physically active women had a 34–47 percent reduction in adjusted odds of DCIS. There was no consistent association between use of hormone replacement therapy and DCIS incidence. The Women’s Health Initiative, which randomized post-menopausal women to hormone replacement therapy (HRT) or not, has not commented to date on the impact of HRT on DCIS incidence. This pattern of no impact of HRT on DCIS incidence is in stark contrast to the increased incidence of invasive breast cancer associated with HRT. The association between use of oral contraceptives after 35 years of age and DCIS was significant in the World Health Organization (WHO) Collaborative Study of Neoplasia and Steroid Contraceptives but not associated in a case-control study based on the state cancer registry in the United States. The studies that examined the association between DCIS and age at first live birth compared to less than 20 years found a significant increase in the risk of DCIS among those who had their first child between 20 and 29 years and more than 30 years of age but not among other age categories. Women with four or more children had a 38 percent decreased risk of DCIS. Women with a family history of breast cancer or who were carriers of the BRCA mutations also had higher rates of DCIS than women with no history.

Randomized trials of tamoxifen or raloxefene for the primary prevention of breast cancer have shown mixed results for preventing DCIS. Studies, such as the Study of Tamoxifen and Raloxefene (STAR), Multiple Outcomes of Raloxefene Evaluation (MORE), and Continuing Outcomes Relevant to Evista (CORE), along with the NSABP P-1 trial, all show tamoxifen to be effective in preventing both invasive breast cancer and DCIS. Raloxefene, in contrast, while associated with decreased risk of invasive breast cancer is not associated with decreased incidence of DCIS.

The presence of multicentric disease is generally considered a contraindication to breast-conserving surgery. Thus, when magnetic resolution imaging (MRI) detects multicentric disease in women with DCIS, treatment recommendations for some patients will be influenced. Among patients with DCIS, the sensitivity of detecting multicentric disease is generally higher with MRI as opposed to mammography. Breast MRI can potentially influence treatment decisions by providing more accurate information on the size and extent of the known DCIS. Such findings may determine the choice of breast-conserving surgery versus mastectomy or the width of excision margins. In addition, accurate preoperative assessment of tumor size may reduce the need for subsequent surgery to excise involved margins. Given the growth pattern of DCIS, accurate histological determination of size and extent can be difficult. Moreover, limitations inherent in tissue processing make tumor measurement difficult. Finally, determining DCIS size is limited by the difficulty in reconstructing the 3-diminsional extent using 2-dimensional pathology slides. As a result, pathological examination can overestimate and underestimate tumor sizes depending on the plane of section. Some authors have argued that MRI measurements may be more accurate than those in the pathology laboratory. There is a low level of evidence that MRI does not improve patient outcomes in women with DCIS and a low level of evidence that treatment utilization was changed according to MRI results in 20–25 percent of women with DCIS. The results of studies comparing mammography with MRI have not been consistent, with some reporting that MRI was equivalent to mammography and others reporting that MRI is more accurate for determining the extent of DCIS.

The overall incidence of sentinel lymph node (SLN) metastases is unknown, but one study reported the overall incidence of SLN metastases to be 9 percent. The incidence of SLN metastases was higher for patients with ductal carcinoma in situ with microinvasion (DCISM) compared with those with DCIS. The incidence of pN1 metastases was very low for patients with pure DCIS. Methodological problems, including small numbers and use of highly selected patients, make evaluation of sentinel lymph node biopsy (SLNB) for DCIS challenging. We were unable to find any study that directly compared important patient outcomes (survival, recurrence, and quality of life) after SLNB versus no SLNB.

In a previous review by the Agency for Healthcare Research and Quality (AHRQ), 24 percent of stereotactic-guided automatic gun core needle biopsies that resulted in a diagnosis of DCIS were found to have invasive cancer upon surgical excision. For stereotactic guided vacuum-assisted core needle biopsy this rate was 13 percent. The incidence of SLN metastases was 5 percent for women with an original diagnosis of DCIS and a final diagnosis of invasive cancer. However, all patients with SLN metastases had a final diagnosis of invasive breast cancer after excision or mastectomy; thus, no women with a final diagnosis of DCIS had SLN metastases. Since about 15 percent of patients with DCIS identified on core needle biopsy are diagnosed with invasive breast cancer after excision or mastectomy, the feasibility and accuracy of SLN biopsy after excision is relevant to decisions regarding surgical management of DCIS. Most studies demonstrate that SLN biopsy is feasible after excision, but the results from studies evaluating the accuracy of SLN after excision are not consistent. An analysis from the National Surgical Adjuvant Breast and Bowel Project (NSABP) B-32, Krag et al. reported that the SLN biopsy false negative rate was significantly increased after excisional biopsy compared with core needle biopsy or fine needle aspiration (needle biopsy, 8.1 percent; excisional biopsy, 15.3 percent).1

The risk factors for DCIS outcomes are different from those for DCIS incidence. Estimates of the impact of the characteristics of women or their tumors on survival show a surprising lack of depth and, with few exceptions, is limited to studies of local DCIS or invasive recurrence. This is likely due to the low incidence of outcomes other than invasive recurrence, even after 10 years. Positive surgical margins are consistently associated with increased DCIS and invasive breast cancer recurrence. In general, larger tumors were associated with higher rates of local DCIS and invasive recurrence than smaller tumors. While labeled somewhat inconsistently, tumors assigned a higher pathological or nuclear grade (3) have a consistently higher probability of local DCIS or invasive recurrence than those at intermediate or low grade (2 or 1). In multiple reports from the same institution using a moderate sized cohort, the lack of calcification was strongly associated with DCIS or invasive carcinoma recurrence. Younger age at diagnosis is a consistent adverse prognostic factor for DCIS outcomes. Women over age 50 consistently have reduced risk of DCIS or invasive recurrence than younger women. The association between positive family history and DCIS or invasive breast cancer recurrence was reported in four studies.

Studies of racial differences in DCIS recurrence paint a somewhat complex story. When adjusting for demographic factors alone, African American women are more likely than white women to experience a recurrence. However, the studies that adjust for a more detailed set of tumor factors find no difference between racial groups. This suggests that there may be differences in the tumors between African American and white women. This finding needs to be further explored. There is only one study reporting outcomes after DCIS diagnosis for Native American women, and that study included only 82 subjects. Further work is needed to examine the outcomes of DCIS in this population.

Several markers of tumor aggressiveness in invasive breast cancer are not well studied in DCIS. Estrogen receptor (ER) positivity has been linked with a decreased risk of recurrence in several small studies. The rate of ER testing, however, is quite low (20 percent). Ongoing trials of tamoxifen and aromitase inhibitors may contribute to more routine testing of ER status in the future.

Her2 positivity has been linked to increased risk of recurrence. This also is rarely tested and has been reported in small studies only. The promise of treating Her2 positive tumors with trastuzumab is being studied in ongoing trials and points to the possibility that Her2 evaluation in women with DCIS might become more common.

Studies of treatment show that outcomes are superior for women whose DCIS is treated rather than untreated. Whole breast radiation therapy following breast conserving surgery (BCS) is associated with a reduction of local DCIS or invasive carcinoma recurrence but has no impact on breast cancer mortality or total mortality. Randomized trials, including NSABP-17, report that whole breast radiation therapy following breast conserving surgery is associated with a reduction of local DCIS or invasive carcinoma recurrence but had no impact on breast cancer mortality or total mortality. Both randomized and observational studies consistently reported a statistically significant decrease in local DCIS or invasive carcinoma associated with receiving whole breast radiation therapy (RT) after BCS. The population impact of the additional treatment of approximately 114 recurrences per 1,000 women treated would be avoided over 10 years through use of radiation. No trial has found a reduction in breast cancer or all cause mortality associated with the use of RT following BCS. RT did not eliminate the impact of adverse prognostic factors such as involved margins and tumor size. Multiple observational studies confirm lower rates of local DCIS or invasive cancer for women undergoing BCS+RT over BCS alone. We found no study suggesting that the relative effectiveness of BCS+RT versus BCS alone is different in the presence of adverse prognostic factors such as larger or high grade tumors, positive margins, or comedo necrosis.

While not studied in a randomized fashion, several observational studies compared outcomes between mastectomy and BCS or BCS+RT. They found women undergoing mastectomy were less likely than women undergoing lumpectomy plus radiation to experience local DCIS or invasive recurrence. Women undergoing BCS alone were also more likely to experience a local recurrence than women treated with mastectomy. We found no study showing a mortality reduction associated with mastectomy over breast conserving surgery with or without radiation. This lack of benefit is particularly striking since clinically larger, multicentric, and more problematic tumors will be more likely to be treated with mastectomy than BCS with or without radiation.

The NSABP-24 assessed the value of tamoxifen following DCIS diagnosis and found it reduces risk of recurrent DCIS or invasive carcinoma. The trial found that tamoxifen was associated with a 50 percent reduction in contralateral disease and of breast cancer mortality but had no impact on all-cause mortality. Adverse events were consistent with tamoxifen’s usual profile.

Clinical issues that are the subject of ongoing investigations are the value of aromitase inhibitors for preventing local DCIS or invasive recurrence or contralateral disease. Finally, trials are examining whether trastuzumab (herceptin) is effective in treating DCIS that is Her2 positive. These trials would benefit the 26 percent of women whose tumors are positive for this adverse prognostic indicator.

There are also ongoing trials examining whether accelerated partial breast irradiation (APBI) is equivalent to whole breast irradiation for treating DCIS. There are three accelerated radiation protocols, all of which reduce the time needed to complete therapy from 6½ weeks for whole breast radiation therapy to between 1 and 5 days. The treatment is focused on the area immediately around the lumpectomy site, the area where recurrences are most likely to occur. Three approaches to APBI are currently being investigated: Intraoperative Radiotherapy (IORT)—1 day of treatment, Intracavitary Brachytherapy (MammoSite^®^)—5 days of treatment, and 3-D Conformal/External Beam Radiotherapy—5 days of treatment.

## Future Research

Important scientific questions that deserve further investigation include gaining a better understanding of the relationship between mammography use and DCIS incidence, whether it is possible to modify current imaging technologies or screening guidelines to better identify lesions that are unlikely to become clinically problematic as well as tumors that are likely to contain some invasive component.

The following proposed recommendations are organized by the original questions:

### Question 1. What are the incidence and prevalence of DCIS and its specific pathologic subtypes, and how are incidence and prevalence influenced by mode of detection, population characteristics, and other risk factors?

1. Is DCIS over-diagnosed? Does diagnosis of DCIS represent an opportunity to prevent invasive breast cancer? Is screening specifically for DCIS important?
2. Is it possible to distinguish between DCIS that is likely to progress and DCIS that is unlikely to progress? Can molecular profiles determine the clinical behavior of DCIS?
3. Is it possible to use existing imaging technologies to distinguish between invasive and noninvasive cancer or between problematic and less problematic lesions?
4. The most appropriate methods and time intervals to screen women at high risk of breast cancer with mammography or MRI are not well established. The value of MRI screening in high risk populations is unclear and should be addressed in future research.
5. Pharmacological prevention of DCIS with tamoxifen or aromitase inhibitors requires future investigation. One study found that while drug administration was effective in preventing DCIS, the effect was not maintained once drug use stopped. Future research should clarify long-term effects of chemoprevention on incident DCIS especially in women with high baseline risk of breast cancer

### Question 2. How does the use of MRI or SLNB impact important outcomes in patients diagnosed with DCIS?

1. Can breast MRI (or other preoperative imaging evaluations) accurately predict invasive breast cancer among DCIS patients originally diagnosed with core needle biopsy? Since invasive breast cancer is treated differently than DCIS, accurate preoperative determination can influence treatment decisions (i.e., SLN biopsy).
2. Can breast MRI identify key factors that can assist with choice of surgical treatment more accurately than mammography?
3. Among patients with a final diagnosis of DCIS or DCISM, what is the clinical significance of pN0(i+) or pN1mic SLN metastases? Do these patients have a worse prognosis? Should axillary lymph node dissection be performed for these women? Should these women be considered to have invasive cancer or be treated as cases of DCIS?

### Question 3. How do local control and systemic outcomes vary in DCIS based on tumor and patient characteristics?

1. Does the risk of local DCIS recurrence, invasive cancer, contralateral disease, or breast cancer mortality change with time from initial diagnosis? The answer has important implications for a discussion of the optimum post-diagnostic surveillance strategy. The optimum surveillance/screening strategy depends to a great extent on how the risk changes over time and how the sensitivity and specificity of current screening modalities can be optimized.
2. What factors are behind differential patterns of DCIS recurrence between African American and white women? The ability to eliminate much of the apparent disparity in outcomes points to important differences in tumors between African American and white women. Whether these differences are modifiable (e.g., tumor size, positive margins) or nonmodifiable (grade, ER status) is unclear. There is presently a total lack of information about DCIS in Native American women. The key question for this group is simply, how are Native American women experiencing DCIS?
3. Are the similarities between prognostic factors for DCIS and invasive breast cancer great enough to recommend similar diagnostic workups or is there value in creating a DCIS-specific prognostic index?
4. Is there value in routine testing of ER and Her2 status for DCIS?

### Question 4. In patients with DCIS, what is the impact of surgery, radiation, and systemic treatment on outcomes?

1. Given that the lack of evidence that BCS+RT provides any mortality benefit and the number of local DCIS or invasive recurrences per 1,000 women treated is small, is there benefit in routine use of RT following BCS?
2. What is the role of partial breast radiation? What is the preferred technique of partial breast radiation?
3. Since RCTs show that RT after BCS does not remove the negative prognostic impact of positive margins, understanding the optimum management to counteract this effect is essential. What is the optimum definition of positive margins? Should patients with close margins undergo re-excision?
4. The role of tamoxifen and aromatase inhibitors is of current interest and will be influenced by the ongoing NSABP trials. Is the benefit of tamoxifen or aromitase inhibitors to provide treatment for the primary DCIS or primary prevention for a future new primary DCIS or invasive cancer. This question acknowledges that history of DCIS or invasive breast cancer is a risk factor for DCIS or invasive cancer incidence.