# Recommendations

## What are the Most Critical Research Questions for the Diagnosis and Management of DCIS?

Table 37 summarizes the research findings to date and suggests future direction. The following more detailed list of proposed recommendations (which expands on the table) are organized by the original questions:

Table 37 Future research recommendations

Key Question | Results of Literature Review | Types of Studies Needed to Answer Question | Future Research Recommendations
1. How is the incidence and prevalence of DCIS influenced by detection, population, and other risk factors? | DCIS incidence has risen dramatically. Not all the increase can be attributed to increased screening. Many risk factors for DCIS are similar to those for invasive cancer. Breast density is a strong risk factor. Role of HRT is less clear. | Observational studies Clinical trials | 1. Studies of risk factors for DCIS such as tobacco, diet, and BMI are needed.; 2. Studies of protective factors are needed; 3. Careful pathological re-examination to see how often DCIS is over-diagnosed; 4. New imaging technologies; 5. Models of screening to maximize efficiency; 6. Prevention trials with tamoxifen or aromatize inhibitors
2. How does the use of MRI or sentinel lymph node biopsy affect outcomes? | Post-diagnostic MRI can improve treatment planning Diagnostic role of MRI in DCIS is less clear Given error rate of needle biopsy SLNB may be useful | Clinical trials | 1. Can breast MRI predict invasive cancer after core needle biopsy?; 2. Can breast MRI predict response to treatment?; 3. Do results of SLNB affect treatment and clinical outcomes for DCIS?
3. How do DCIS outcomes vary with tumor and patient characteristics? | Risk factors for DCIS outcomes similar to those for invasive cancer All-cause mortality for African Americans with DCIS is higher than those for white women Positive surgical margins are associated with poorer outcomes Markers of tumor aggressiveness are not well studied in DCIS | Observational studies | 1. Is the risk of recurrence of DCIS linear?; 2. Do ER status and Her2 status predict outcomes in DCIS?; 3. Are differences in outcomes between African American and white women explainable by factors such as tumor size, ER status, positive margins, tumor grade?; 4. Is a specific prognostic index for DCIS needed?
4. In DCIS patients how do surgery, radiation, and systemic treatment affect outcomes? | BCS+RT reduces local recurrence rates but does not improve mortality over BCS alone RT after BCS does not improve the negative risks of positive margins Mastectomy seems to produce slightly better outcomes than BCS+RT | Clinical trials | 1. What are the effects of partial breast radiation?; 2. Should patients with close margins undergo re-excision?; 3. Can tamoxifen or aromatase inhibitors benefit DCIS> In what cases?

### Question 1

- 1. Is DCIS over-diagnosed? Does diagnosis of DCIS represent an opportunity to prevent invasive breast cancer? Is screening specifically for DCIS important?
- 2. Is it possible to distinguish between DCIS that is likely to progress and DCIS that is unlikely to progress? Can molecular profiles determine the clinical behavior of DCIS?
- 3. Is it possible to use existing imaging technologies to distinguish between invasive and noninvasive cancer or between problematic and less problematic lesions?
- 4. The most appropriate methods and time interval to screen women at high risk of breast cancer with mammography or MRI are not well established. The value of MRI screening in high risk populations is unclear and should be addressed in future research.
- 5. Pharmacological prevention of DCIS with tamoxifen or aromitase inhibitors requires future investigation. One study found that while drug administration was effective in preventing DCIS the effect was not maintained once drug use stopped. Future research should clarify long-term effects of chemoprevention on incident DCIS especially in women with high baseline risk of breast cancer

### Question 2

- 6. Can breast MRI (or other preoperative imaging evaluations) accurately predict invasive breast cancer among DCIS patients originally diagnosed with core needle biopsy? Since invasive breast cancer is treated differently than DCIS, accurate preoperative determination can influence treatment decisions (i.e., SLN biopsy).
- 7. Can breast MRI identify key factors that can assist with choice of surgical treatment more accurately than mammography?
- 8. Among patients with a final diagnosis of DCIS or DCISM, what is the clinical significance of pN0(i+) or pN1mic SLN metastases? Do these patients have a worse prognosis? Should axillary lymph node dissection be performed for these women? Should these women be considered to have invasive cancer or be treated as cases of DCIS?

### Question 3

- 9. Does the risk of local DCIS recurrence, invasive cancer, contralateral disease, or breast cancer mortality change with time from initial diagnosis? The answer has important implications for a discussion of the optimum post-diagnostic surveillance strategy. The optimum surveillance/screening strategy depends to a great extent on how the risk changes over time and how the sensitivity and specificity of current screening modalities can be optimized.
- 10. What factors are behind differential patterns of DCIS recurrence between African American and white women? The ability to eliminate much of the apparent disparity in outcomes points to important differences in tumors between African American and white women. Whether these differences are modifiable (e.g., tumor size, positive margins) or nonmodifiable (grade, ER status) is unclear. There is presently a total lack of information about DCIS in Native American women. The key question for this group is simply, how are Native American women experiencing DCIS?
- 11. Are the similarities between prognostic factors for DCIS and invasive breast cancer great enough to recommend similar diagnostic workups, or is there value in creating a DCIS-specific prognostic index?
- 12. Is there value in routine testing of ER and Her2 status for DCIS?

### Question 4

- 13. Given the lack of evidence that BCS+RT provides any mortality benefit and the number of local DCIS or invasive recurrences per 1,000 women treated is small, is there benefit in routine use of RT following BCS?
- 14. What is the role of partial breast radiation? What is the preferred technique of partial breast radiation?
- 15. Since RCTs show that RT after BCS does not remove the negative prognostic impact of positive margins, understanding the optimum management to counteract this effect are essential. What is the optimum definition of positive margins? Should patients with close margins undergo re-excision?
- 16. The role of tamoxifen and aromatase inhibitors is of current interest and will be influenced by the ongoing NSABP trials. Is the benefit of tamoxifen or aromatase inhibitors to provide treatment for the primary DCIS or primary prevention for a future new primary DCIS or invasive cancer. This question acknowledges that history of DCIS or invasive breast cancer is a risk factor for DCIS or invasive cancer incidence.