# Methods

## Literature Search Strategy and Eligibility Criteria

### Search Strategy

Studies were sought from a wide variety of sources, including MEDLINE^®^ via PubMed^®^,18 Scirus,19 Cochrane databases,20 websites of the Sloane Project and of the International Breast Cancer Screening Network (IBSN), and manual searches of reference lists from systematic reviews and consensus conferences. We searched the database of the registered clinical trials www.clinicaltrials.gov to identity ongoing research relevant for question 5.

We updated our search in February 2009 and requested a controlled expert search in February 2009 to compare sensitivity of our different search strategies. The search strategies for the four research questions are described in Appendix A. Excluded references are shown in Appendix B. All work was conducted under the guidance of a Technical Expert Panel (TEP), whose members are identified in Appendix C.

### Eligibility

Three investigators independently decided on the eligibility of the studies according to recommendations from the Cochrane manual for systematic reviews.21 The algorithm to define eligibility of the studies was developed for each research question (Appendix D). We reviewed abstracts to exclude the studies of exclusively invasive breast cancer, nonbreast ductal cancers (e.g., pancreatic ductal cancer), animal or in vitro experiments, analysis of results taken directly from other publications, letters, comments, and case reports. We confirmed the eligible target population of female adults. The epidemiologic studies published in the English language between 1965 and February 2009 were examined to identify studies with eligible outcomes. These outcomes were defined as the incidence of DCIS and rates of mastectomy, breast conserving therapy, radiation therapy, chemotherapy, and hormonal therapy use. These studies also identified rates of metastases,22 in-breast recurrence for question 2, and local, regional, and distant recurrence, contralateral disease, disease-specific and overall survival, or changes in tumor size based on imaging for questions 3 and 4 (operational definitions in Appendix D). For question 1, we included population based studies that examined incidence of DCIS standardized per 100,000 female population, per 1,000 screened women, or incident cases of DCIS among screened population (population denominator). We included cohort, cross-sectional and case-control studies that examined risk factors for DCIS. For question 2 we included all observational studies that reported outcomes after SLNB in women with initial or final diagnosis of DCIS. We also included all observational studies of pre-surgical MRI in women with DCIS to detect multicentric (multifocal) or bilateral breast cancer. For question 3 we included the studies of untreated DCIS (natural history) and the studies that reported rates of eligible outcomes independent of (adjusted for) treatments among subpopulations with different specimen radiography features, margin status, tumor size, histological grade, estrogen or progesterone receptor status, volume of tumor evaluated, or breast density. We also included studies that reported rates of eligible outcomes in subgroups of different age, race, genetic predisposition, or menopausal status after adjustment for treatment status. For question 4 we included original studies that examined the effects of mastectomy, lumpectomy, radiation, or their combinations, and administration of tamoxifen, raloxifene, and aromatase in women with DCIS. We excluded studies that did not test associative hypotheses and did not provide adequate information on tested hypotheses (e.g., least square means, relative risk).

Finally, we confirmed eligible levels of evidence for each research question. The following inclusion criteria were used to select articles for full review: For questions of incidence of DCIS large population-based cross sectional or cohort studies and analyses of population-based cancer registries or nationally representative administrative databases were selected. For the question of risk factors of DCIS we also included baseline data from clinical trials and case control studies. We selected observations of crude DCIS incidence among women at very high risk of breast cancer, including genetic predisposition and prophylactic mastectomy. We did not exclude the studies that reported incidence of DCIS among small samples of patients with Paget disease, other malignant neoplasms (lymphoma), or radial scars. For the question of SLNB we included all studies (case series) independent of the number of DCIS cases or internal validity of the reports. For the question on MRI we prioritized the studies that aimed to examine sensitivity and specificity of MRI to detect multicentric or bilateral cancer in patients with DCIS and the studies of treatment decisions based on MRI; however, we did not exclude any study that reported other MRI outcomes (tumor size, MRI patterns) in DCIS cases. For the question on natural history of DCIS we intended to select any longitudinal study that reported eligible outcomes in untreated women. For the questions on the effects of clinical interventions we selected randomized controlled clinical trials, multicenter nonrandomized clinical trials, and observational studies with more than 100 cases of DCIS; however, we did not exclude any study that reported the rates of eligible outcomes among patients with DCIS.

The exclusion criteria included the following:

- Studies with target populations, such as children, adolescents, males, females with lobular carcinoma in situ or invasive breast cancer.
- Studies that examined the distribution of histo-pathological types of DCIS among patients with breast cancer (all breast cancer in denominator).
- Studies that evaluated the association between levels of biological markers of breast cancer and cancer progression (DCIS versus invasive cancer).
- Studies that reported absolute levels of biological markers of tumor or angiogenesis in breast cancer patients.
- Studies that did not report rates of patient outcomes but evaluated treatment utilization or women’s perception and knowledge about treatment options.

We conducted a pilot test to assess agreement in eligibility status among the principal investigator and research assistants. We detected the reasons for disagreement to clarify eligibility criteria. The principal investigator reviewed randomly selected excluded cohort studies and clinical trials to confirm eligibility status.

### Quality Assessment

Study quality was analyzed using the framework recommended in the manual of comparative effectiveness reviews (http://effectivehealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf)

Stage 1. Classification of the study design.

1. Is the study comparative?
2. Did investigators assign the exposure? If so, was the intervention allocated randomly?
  Was randomization done at the individual level? If not, was more than one group of subjects studied? Were exposure and outcome assigned at the same time? Were groups assigned by exposure or by outcome?

Based on the answers to these questions, we classified the studies as:

1. Interventions. Randomized controlled trial (RCT) (I level of evidence)23 or nonrandomized controlled clinical trial (IA level of evidence) or nonrandomized uncontrolled clinical trial.
2. Observations

Cohort (prospective) study with concurrent controls (II-2A level of evidence). The study had defined populations which were prospectively followed in an attempt to determine distinguishing subgroup characteristics. The sufficient populations were observed over a sufficient number of years to generate incidence rates subsequent to the selection of the study group.

Cohort (retrospective) study with concurrent controls (IIC level of evidence). The study had defined populations which were retrospectively followed in an attempt to determine distinguishing subgroup characteristics. The essential feature is that some of the persons under study have the disease or outcome of interest and their characteristics are compared with those of unaffected persons.22

Case control (retrospective) study. The study started with the identification of persons with a disease of interest and a control (comparison, referent) group without the disease. The relationship of an attribute to the disease was examined by comparing diseased and nondiseased persons with regard to the frequency or levels of the attribute in each group.

Cohort (prospective) study with historical controls (IIB level of evidence). The study had defined populations which were prospectively followed in an attempt to determine distinguishing population characteristics with historical controls.

Nested case control. The study started with the identification of persons with a disease of interest and a control (comparison, referent) group without the disease that were identified within the cohort of the subjects, participants in prospective cohort study. The relationship of an attribute to the disease was examined by comparing diseased and nondiseased persons with regard to the frequency or levels of the attribute in each group.

Cross-sectional study. The study determined the association with a disease at one particular time point.

Stage 2. Abstract predefined criteria for quality for critical appraisal.24–26 We evaluated quality of observational studies using criteria of internal and external validity.27 We evaluated quality of interventional studies using criteria from the Cochrane manual,21 including randomization, adequacy of randomization and allocation concealment, masking of the treatment status, intention to treat principles, and justification of the sample size. We abstracted the following criteria of internal validity: masking of the treatment status, preplanned intention to treat analysis, adequacy of allocation concealment, randomization scheme, adequacy of randomization, similarity of comparison groups, validation of the methods to measure the outcomes, loss of followup, strategy to reduce bias in design, control for confounding factors in analyses, and reported estimates (crude, adjusted).

Stage 3. Ratings of quality of individual studies. We rated quality of the studies based on the CER manual (available at http://www.effectivehealthcare.ahrq.gov/healthInfo.cfm?infotype=rr&ProcessID=60).

Well designed (good- low risk of bias). These studies have the least bias and results are considered valid. A study that adheres mostly to the commonly held concepts of high quality, including the following: a formal randomized controlled study; clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; low dropout rate; and clear reporting of dropouts.

Fair. These studies are susceptible to some bias, but it is not sufficient to invalidate the results. They do not meet all the criteria required for a rating of good quality because they have some deficiencies, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.

Poor (high risk of bias). These studies have significant flaws that imply biases of various types that may invalidate the results. They have serious errors in design, analysis, or reporting; large amounts of missing information; or discrepancies in reporting.

### Rating the Body of Evidence

We rated body of evidence following the guidelines from the CER manual, the Grading of Recommendations Assessment, Development, and Evaluation (GRADE) Working Group,24,25 and the U.S Preventive Task Force criteria.23

First, we evaluated a risk of bias based on

A. Individual study design (RCT, prospective cohort, retrospective cohort or case control studies, cross-sectional study, case series)
B. Quality of the study

We considered properly designed RCTs to provide unbiased estimations of the causal effects of the treatments on patient outcomes. Well designed prospective cohorts with concurrent controls and multivariate analysis of the associations resulted in low risk of bias estimations of the association between risk factors and incidence of DCIS or between treatments and patient outcomes. Well designed retrospective cohorts with concurrent controls or case control studies with randomly selected population based controls and multivariate analysis of the associations resulted in estimations of the associations with a medium risk of bias. Cross-sectional comparisons and crude estimations were considered to have a high risk of bias.

Then we evaluated consistency in the associations defined as the degree to which reported effect sizes from included studies appear to go in the same direction with the narrow range of effect size (precision). Consistent results from unbiased studies or studies with low risk of bias were defined as high level of evidence. Consistent results from studies with medium risk of bias were defined as moderate level of evidence. Inconsistent results from RCTs or prospective cohorts as well as consistent results from the studies with high risk of bias were defined as low level of evidence. All indirect comparisons were considered as low level of evidence.

We applied the GRADE criteria to lower level of evidence for imprecise or sparse data if the results include few events of the outcomes or to increase the level of evidence for significant dose response associations. We did not calculate formal scores for therapeutic studies with different design and quality.

The final evaluation of the body of evidence defined high level of evidence when further research is very unlikely to change our confidence in the estimate of effect, moderate level of evidence if further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate, and low level of evidence if further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.

### Applicability

Applicability of the population was estimated by evaluating a selection of subjects in observational studies and clinical trials.27 We abstracted the following criteria of external validity: source of patients, adequacy of the sampling (random selection or not), response rate, sampling bias assessment, description of sampling bias when detected as differences between study sample and target population as reported by authors, results of assessment of sampling bias, and inclusion and exclusion criteria. We considered that the studies of incidence of DCIS that were conducted in the United States had the highest applicability. Large observational cohorts based on national registries, population-based surveys, and nationally representative administrative and clinical databases or cancer registries had high applicability. Applicability of the intervention duration was high for studies with followup of 1 year or more and acceptable for studies with followup of 6–12 months.

### Data Extraction

Evaluations of the studies and data extraction were performed manually and independently by four researchers. The data abstraction forms are shown in Appendix E. Errors in data extractions were assessed by a comparison with the established ranges for each variable and the data charts with the original articles. Any discrepancies were detected and discussed. Quality control was conducted by the researchers. We abstracted incidence of DCIS as reported by the authors, including number of incident DCIS cases, age-adjusted rates of DICS per 1,000 screened or per 100,000 standardized female population. We abstracted cumulative incidence during the study period to estimate annual incidence rates. We abstracted the number of patients with outcomes per treatment status and patient or tumor characteristics to calculate rates of the outcomes, relative risk, or absolute risk difference with 95 percent confidence intervals (CI). We abstracted adjusted relative measures of the association as reported relative risk, odds ratio, or hazard rate ratio. We abstracted the number randomized to each treatment group as the denominator to calculate estimates applying the intention to treat principle.28 We abstracted the time when the outcomes were assessed as weeks from randomization and the time of followup post treatment. We extracted author reported adjustments for patient age, race, gender, confounding factors, and treatment status.

### Data Synthesis

The results of individual studies were summarized in evidence tables (Appendix F).

Baseline data were compared in different studies to test differences in the target population and unusual patterns in the data.29,30 Regression coefficients, and 95 percent CI were calculated from reported means, standard errors, and sample size.28,31

Pooling criteria included the same operational definitions of outcomes and the same risk factors or clinical interventions.32 Meta-analysis was used to assess the consistency of the association between risk factors and incidence of DCIS and between treatments and outcomes with random effects models.33 We conducted analyses separately for relative measures of the associations in logarithmic scale, events of clinical outcomes among those exposed and nonexposed to risk factors or treatments, and for rates of positive sentinel node biopsy in women with initial and final diagnosis of DCIS to calculate prevalence with 95 percent CIs in logarithmic scale. Assumptions underlying meta-analysis included valid measurements of the outcomes and similarity in study and target populations. The protocol for the meta-analyses was created according to recommendations for meta-analysis of RCTs (the Quality of Reporting of Meta-analysis [QUOROM] statement)34 and observational studies (Meta-analysis of Observational Studies in Epidemiology [MOOSE] statement35).

We tested consistency in the results comparing the direction and strength of the association. Chi squared tests and I squared tests were used to assess heterogeneity.36,37 Calculations were performed using STATA software,38 SAS 9.2, and Meta-analyst software (available at https://research.tufts-nemc.org/metaanalyst/) at the 95 percent confidence level. We calculated the number needed to treat and the number of events attributable to the treatments per 1,000 treated.39

We assumed the presence of publication bias and did not use statistical tests for bias defined as the tendency to publish positive results and to predict association when all conducted (published and unpublished) studies are analyzed.40–43 We used several strategies to reduce bias, including a comprehensive literature search of published evidence in several databases, reference lists of systematic reviews, contacts with experts for additional references they might provide, and agreement on eligibility status by several investigators.