# Introduction

## Overview

Ductal carcinoma in situ (DCIS) is noninvasive breast cancer that encompasses a wide spectrum of diseases ranging from low-grade lesions that are not life threatening to high-grade lesions that may harbor foci of invasive breast cancer. DCIS is characterized histologically by the proliferation of malignant epithelial cells that are bounded by the basement membrane of the breast ducts. DCIS has been classified according to architectural pattern (solid, cribriform, papillary, and micropapillary), tumor grade (high, intermediate, and low grade), and the presence or absence of comedo histology. Prior to the advent of widespread screening mammography, DCIS was usually diagnosed by surgical removal of a suspicious breast mass. DCIS was rarely diagnosed before 1980,^2^ but currently about 25 percent of breast cancers diagnosed in the United States are DCIS (Figure 1).3

Figure 1 Trends in the incidence of DCIS and invasive cancer (1975–2005)4

While studies of the natural history of invasive breast cancer are rare, there is general consensus that DCIS represents an intermediate step between normal breast tissue and invasive breast cancer. Since excisional biopsy (and, to a lesser extent, core needle biopsy) removes a significant portion of the targeted lesion, the natural history of untreated DCIS is unknown. Data from both randomized trials and population-based studies indicate that the 10-year breast cancer mortality rate for patients with DCIS is less than 2 percent after excision or mastectomy.5,6 The percentage of DCIS that is ‘nonprogressing,’ that is, would not develop into invasive disease even if untreated, is unknown. A recently published Markov model that incorporates data from multiple mammography screening trials estimates the incidence of DCIS that will progress into invasive breast cancer if untreated at 100–270 per 100,000. The model estimates that women can survive with nonprogressing DCIS for over 30 years while the average time prior to progressing from DCIS to invasive cancer is 3 months. The model further assumes that these invasive breast cancers will remain in a preclinical state, on average, for 2½ years. Thus, women with progressing DCIS have slightly less than 3 years between DCIS incidence and clinically detected invasive breast cancer.7 This estimate is somewhat shorter than the observed 7 years for overall breast cancer (in situ and invasive) to equalize in the Swedish Two-county Trial.8

DCIS is usually identified by the presence of microcalcifications on mammograms. Invasive breast cancer is usually identified as a mass on mammography. Image guided core needle biopsy is usually performed to obtain histological confirmation of DCIS or invasive breast cancer. Some patients with an original diagnosis of DCIS on core needle biopsy will have a final diagnosis of invasive breast cancer after excision or mastectomy. A structured literature review sponsored by AHRQ reviewed all articles assessing the accuracy of needle biopsy for DCIS and breast cancer. The study reviewed more than 100 studies and concluded that 24 percent of tumors with DCIS identified from stereotactic-guided automatic gun core needle biopsy were found to have invasive breast cancer upon surgical excision (95 percent CI 0.18; 0.32).9 For stereotactic guided vacuum-assisted core needle biopsy this rate was 13 percent (95 percent CI 0.11; 0.15).

Although DCIS may look to be a small lesion on mammograms, the disease frequently extends along the ducts and may involve a large portion of the breast with multiple foci. For some patients, mammography can grossly underestimate the extent of DCIS. Improvements in the preoperative assessment of patients with DCIS may refine clinical decisionmaking.

## Imaging and Treatment for Women with Invasive Breast Cancer

Although this report focuses on DCIS, some examination of invasive breast cancer is relevant for two reasons: (1) Since no one sets out specifically to look for DCIS, the clinical strategies overlap. The initial efforts at detection cannot separate the two conditions until the process has advanced and a biopsy is obtained. Even then the distinction may be difficult. (2) To a great extent treatment of DCIS is modeled after the modalities used for invasive breast cancer, but many of the areas explored for invasive breast cancer have not been similarly explored for DCIS.

Breast magnetic resonance imaging (MRI) is increasingly used in the pretreatment evaluation of patients with invasive breast cancer. The primary objectives of breast MRI for women diagnosed with invasive cancers are: (1) to detect ipsilateral multicentric disease; (2) to determine the extent of the known cancer; and (3) to evaluate the contralateral breast. The treatment of invasive cancer may be modified by MRI findings, which may lead to wider excisions, unilateral mastectomy, and/or treatment of the contralateral breast.

Mastectomy is generally recommended for patients with diffuse microcalcifications (>4 cm), multicentric disease (involving more than one breast quadrant) (http://www.nccn.org) or if their surgeon is unable to obtain negative surgical margins with breast conserving surgery. A series of randomized trials in the 1980s followed by a National Institutes of Health (NIH) Consensus Conference established that breast conserving surgery (BCS) combined with radiation therapy resulted in equivalent survival as mastectomy for women with early stage invasive breast cancer.10–16 The original trials found that radiation therapy (RT) after BCS decreased local recurrences but did not show a mortality benefit of BCS+RT compared with BCS alone. A recent meta-analysis by the Early Breast Cancer Trialists’ Collaborative Group, however, found BCS+RT reduced mortality as well as local recurrence. The use of BCS (excision) as compared with mastectomy has increased in recent years for invasive breast cancer.17

Approximately 80 percent of tested invasive breast cancers are positive for estrogen receptors (ER), indicating that estrogen contributes to these tumors’ growth. An additional hormonal receptor, the progesterone receptor (PR) is a slightly less important predictor of tumor growth. Most tumors are concordant for estrogen receptor and progesterone receptor (65 percent of ER tumors are also PR positive). From this understanding of the role of estrogen have come endocrine therapies. The two most common classes are: Aromatase inhibitors [Arimidex (chemical name: anastrozole), Aromasin (chemical name: exemestane), Femara (chemical name: letrozole)] and Selective Estrogen Receptor Modulators (SERMs): [tamoxifen, Evista (chemical name: raloxifene), Fareston (chemical name: toremifene)]. The therapies work by lowering the amount of estrogen in the body (Aramitase inhibitors) or blocking the action of estrogen. While different in their side effect profiles and perhaps different in their effectiveness, these therapies have been shown to prevent recurrence of ER + invasive breast cancer and to reduce breast cancer incidence.

For patients with invasive breast cancer, lymph node staging is recommended to determine prognosis and guide treatment decisions. Until the late 1990s, axillary lymph node dissection (ALND) was recommended for most patients with invasive breast cancer to identify and remove lymph node metastases. However, ALND is associated with significant morbidity including nerve injuries and lymphedema; moreover, patients who do not have lymph node metastases don’t benefit from the procedure. In contrast to ALND, sentinel lymph node biopsy (SLNB) is a minimally invasive procedure that identifies axillary node metastases; patients are spared unnecessary ALND if no sentinel lymph node (SLN) metastases are identified. In the past decade SLN biopsy has replaced ALND for most patients with invasive breast cancer.

The lessons learned from invasive breast cancer will be used as a backdrop for the examination of DCIS detection and treatment.

## Defining Key Terms

### Comedo DCIS

Comedo histologic subtype is DCIS that is characterized by prominent apoptotic cell death and has greater malignant potential than other DCIS subtypes.

### Multicentric Disease

The most common definition of multicentric disease is discontinuous tumor presence in multiple breast quadrants.

### DCIS with Microinvasion

DCIS with microinvasion (DCISM) is defined by the American Joint Committee on Cancer (AJCC) as microinvasion 0.1 cm or less in greatest dimension.

### Core Needle Breast Biopsy

Core needle breast biopsy is a percutaneous procedure that retrieves a small sample of breast tissue through a needle.

### Excisional Breast Biopsy

Excision breast biopsy is a surgical procedure that removes the targeted lesion (breast lump or microcalcifications) through an open incision.

## Conceptual Models for the Key Questions

Conceptual models for the key questions are shown in Figures 2–4.

Figure 2 Conceptual model for question 1

Figure 3 Conceptual model for question 2

Figure 4 Conceptual model for questions 3 and 4

Question 1. What are the incidence and prevalence of DCIS and its specific pathologic subtypes, and how are incidence and prevalence influenced by mode of detection, population characteristics, and other risk factors?

Question 2. How does the use of MRI or SLNB impact important outcomes in patients diagnosed with DCIS?

Question 3. How do local control and systemic outcomes vary in DCIS based on tumor and patient characteristics?

Question 4: In patients with DCIS, what is the impact of surgery, radiation, and systemic treatment on outcomes?