# Evidence Tables

Table F1 Incidence of DCIS in population based studies

Study | Recruitment | Outcome | Sample
Lewis, 1975^2^ Country: USA Design: Prospective Cohort Time Period: Not specified | Recruitment: Medical College of Wisconsin, Milwaukee Sampling: Not random Applicability: Subjects were ascertained at a medical school hospital in Milwaukee, Wisconsin | Definition: Noninvasive intraductal carcinoma (also included patients with both intraductal and lobular carcinoma in situ) Diagnosis: Screening, which included a physical examination by trained technologists, thermography and xeromammography Validation: Biopsy | Sample size: 4,500 Length of followup: N/S Range: N/S-N/S Loss of followup: N/A Inclusion age: N/S Level of evidence: IV
Schwartz, 1976^3^ Country: USA Design: Prospective Cohort Time Period: 1973-1975 | Recruitment: Breast Diagnostic Center at Jefferson Medical College Sampling: Not random Applicability: Women were self-referred; subjects were ascertained from one location | Definition: Noninvasive ductal cancer Diagnosis: Clinical examination, xeroradiography, thermography Validation: Biopsy | Sample size: 13,907 Length of followup: 18 months Range: N/S-N/S Loss of followup: N/A Inclusion age: All ages Level of evidence: IV
Feig, 1977^4^ Country: USA Design: Retrospective cohort Time Period: Not specified | Recruitment: Breast Diagnostic Center, Thomas Jefferson University Hospital in Philadelphia, Pennsylvania Sampling: Not random Applicability: Non-generalizable beyond women who went to the Thomas Jefferson University Hospital, unknown study time; women were self-referred | Definition: DCIS Diagnosis: Clinical exam, mammography Validation: Biopsy | Sample size: 16,000 Length of followup: Unknown Range: N/S-N/S Loss of followup: N/A Inclusion age: 45-64 Level of evidence: II-2C
Patchefsky, 1977^5^ Country: USA Design: Prospective Cohort Time Period: 1973-1976 | Recruitment: Thomas Jefferson University Hospital Sampling: Not random Applicability: No patients under age 45 years or over age 64 years, so the study does not reflect the true age range of breast cancer in Philadelphia Race: 90% White, 9% African American | Definition: Intraductal in situ carcinoma Diagnosis: Mammography, thermography, and physical examination Validation: Biopsy | Sample size: 17,526 Length of followup: 31 months Range: N/S-N/S Loss of followup: N/A Inclusion age: 45-64 Level of evidence: IV
Croll, 1977^6^ Country: Australia Design: Retrospective cohort Time Period: 1971-1975 | Recruitment: Medicheck, Sydney Sampling: Not random Applicability: All women were referred by their doctors | Definition: Non-infiltrating intraductal carcinoma Diagnosis: Mammogram Validation: Biopsy | Sample size: 11,927 Length of followup: 59 months Range: N/S-N/S Loss of followup: 0.17 Inclusion age: ≥25 Level of evidence: II-2C
Kreger, 1991^7^ Country: USA Design: Prospective Cohort Time Period: 1948-1986 | Recruitment: Framingham Heart Study Sampling: Not random Applicability: Sampling only occurred in Framingham, Massachusetts | Definition: Noninfiltrating intraductal carcinoma Diagnosis: N/S Validation: FHS file | Sample size: 2,873 Length of followup: 38 years Range: 36-38 years Loss of followup: N/A Inclusion age: 30-62 Level of evidence: II-2A
Simon, 1993^8^ Country: USA Design: Retrospective Cohort Time Period: 1975-1988 | Recruitment: metropolitan Detroit Cancer Surveillances system Sampling not specified Applicability: N/S | Definition: DCIS Diagnosis: Mammography Validation: Not specified | Sample size: Not specified Length of followup: 24months Range: N/S-N/S Loss of followup: N/A Inclusion age: 40-49 Level of evidence: II-2C
Alves, 1994^9^ Country: Portugal Design: Retrospective Cohort Time Period: 1990-1994 | Recruitment: Nucleo Regional do Centro da Liga Portuguesa Contra o Cancro All sampled Applicability: N/S | Definition: DCIS Diagnosis: Mammography Validation: Not specified | Sample size: 6,385 Length of followup: 48 months Range: N/S-N/S Loss of followup: N/A Inclusion age: 45-49 Level of evidence: II-2C
Van Oyen, 1994^10^ Country: Belgium Design: Retrospective Cohort Time Period: 1989 to the beginning of 1992 | Recruitment: The Center for Early Cancer Detection in Antwerp-Limburg All sampled Applicability: N/S | Definition: DCIS Diagnosis: Mammography Validation: Not specified | Sample size: 6,749 Length of followup: 36 months Range: N/S-N/S Loss of followup: N/A Inclusion age: 50-54 Level of evidence: II-2C
Garas, 1994^11^ Country: Greece Design: Retrospective Cohort Time Period: 1989-1990 | Recruitment: The Hellenic Society of Oncology All sampled Applicability: N/S | Definition: DCIS Diagnosis: Mammography Validation: Not specified | Sample size: 3,818 Length of followup: 24 months Range: N/S-N/S Loss of followup: N/A Inclusion age: 45-49 Level of evidence: II-2C
Curpen, 1994^12^ Country: USA Design: Retrospective cohort Time Period: 1985-1994 | Recruitment: Mobile van screening program Sampling: Not random Applicability: Subjects were ascertained in a mobile van screening program which most likely caused selection bias | Definition: DCIS Diagnosis: Mammogram Validation: Pathology reports | Sample size: 4,4301 Length of followup: 109 months Range: N/S-N/S Loss of followup: N/A Inclusion age: 40-64 Level of evidence: I
Tabar, 1995^13^Country: Sweden Design: Randomized controlled clinical trial Time Period: 1977–1990 | Recruitment: The Mammography Department, Central hospital, Falun, Sweden Sampling random Applicability: N/S | Definition: DCIS Diagnosis: Mammography Validation: Not specified | Sample size: 19,844 Length of followup: 156 months Range: N/S-N/S Loss of followup: N/A Inclusion age: 40–49 Level of evidence: I
Faulk, 1995^14^ Country: USA Design: Retrospective cohort Time Period: 1985–1994 | Recruitment: Mobile van mammography program run by University of California School of Medicine, San Francisco Sampling: Not random Applicability: Mammography was performed with a mobile van, therefore many women may not have been reached | Definition: DCIS Diagnosis: Mammogram Validation: Biopsy | Sample size: 32,140 Length of followup: 8 years, 11 months Range: N/S-N/S Loss of followup: N/A Inclusion age: ≥50 Level of evidence: I
Tabar, 1996^15^Country: Sweden Design: Randomized controlled clinical trial Time Period: 1977–1990 | Recruitment: The Mammography Department, Central hospital, Falun, Sweden Sampling: Not random Applicability: Women over 69 were included in the study but were not analyzed | Definition: DCIS Diagnosis: Mammography Validation: Clinical or pathologic records | Sample size: 46,897/15,604 analyzed Length of followup: 156 months Range: N/S-N/S Loss of followup: N/A Inclusion age: 40–69 Level of evidence: I
Kerlikowske, 1996^16^ Country: USA Design: Retrospective cohort Time Period: 1985–1992 | Recruitment: Mobile Mammography Screening Program of the University of California, San Francisco in 6 counties of northern California Sampling: Not random Applicability: Subsequent screening examinations after the first screening were not included in the study sample; breast cancer cases could potentially not be reported if detected if breast cancer detected after normal mammography is not reported to the registry or occurs among women who move out of the 9-county region before their breast cancer is diagnosed; results may not be generalizable to all mammography practices Race: 64% white, 36% nonwhite | Definition: DCIS Diagnosis: Mammography Validation: Biopsy or SEER records | Sample size: 7,306 Length of followup: 83 months Range: N/S-N/S Loss of followup: 0.004 Inclusion age: ≥30 Level of evidence: IV
Zheng, 1997^17^ Country: USA Design: Retrospective cohort Time Period: 1976–92 | Recruitment: Connecticut Tumor Registry Registry Applicability: N/S Race: 95% Caucasians,5% African American | Definition: Ductal carcinoma in situ (ICD-0 8500/2) Diagnosis: Mammography Validation: Not specified | Sample size: N/S Length of followup: 24months Range: 24 -24 Loss of followup: N/A Inclusion age: ≥30 Level of evidence: II-2C
Evans, 1997^18^ Country: USA Design: Retrospective cohort Time Period: 1989–1995 | Recruitment: Susan G. Komen Breast Center at Baylor University Medical Center Sampling: Not random Applicability: Women were only included in the sample if they had a nonpalpable breast lesion in which a needle-wire localization and subsequent surgical biopsy were performed at the facility | Definition: DCIS (cases in which there was DCIS with microinvasion were considered invasive) Diagnosis: Mammography Validation: Needle-wire localization and surgical biopsy | Sample size: 3,734 Length of followup: 7 years Range: N/S-N/S Loss of followup: N/A Inclusion age: All ages Level of evidence: II-2C
Levi, 1997^19^ Country: Switzerland Design: Retrospective cohort Time Period: 1977–1994 | Recruitment: Cancer Registry of the Swiss Canton of Vaud Registry: All sampled Applicability: Lower or under utilization of mammographic screening in this population | Definition: DCIS Diagnosis: N/S Validation: N/S | Sample size: 100,000 Length of followup: 18 years Range: N/S-N/S Loss of followup: N/A Inclusion age: All ages Level of evidence: II-2C
Vizcaino, 1998^20^ Country: Spain Design: Retrospective cohort Time Period: 1992–1996 | Recruitment: Valencia Community All sampled Applicability: N/S | Definition: DCIS Diagnosis: Mammography Validation: Not specified | Sample size: 21,614 Length of followup: 26.8 months Range: N/S-N/S Loss of followup: N/A Inclusion age: 45–49 Level of evidence: II-2C
Han, 1998^21^ Country: Hong Kong Design: Retrospective cohort Time Period: 1993–1995 | Recruitment: Well Women Clinic in Kwong Wah Hospital Sampling: Not random Applicability: Because women themselves decided to get breast cancer screening, there may be a higher proportion of younger women, symptomatic women, women with a positive family history and women who are more health conscious; also not generalizable to other populations besides in Hong Kong | Definition: DCIS Diagnosis: Mammogram Validation: Stereotactic-guided hook-wire biopsies and stereotactic-guided fine needle aspirations (FNA) followed by open biopsies | Sample size: 13,033 Length of followup: 2 years Range: N/S-N/S Loss of followup: N/A Inclusion age: >35 Level of evidence: II-2C
Dershaw, 1998^22^ Country: USA Design: Retrospective cohort Time Period: 1991–1995 | Recruitment: Community-based breast health partnerships organized and funded through the New York State Department of Health Sampling: Not random Applicability: Results may not be generalizable to other populations outside of the New York area; women were eligible if income was at or below two and a half times the income defined as poverty level; eligible if a mammogram had not been performed within 2 years; eligible if there was a lack of insurance coverage | Definition: DCIS Diagnosis: Mammogram Validation: Biopsy | Sample size: 98,573 Length of followup: 20 months Range: N/S-N/S Loss of followup: N/A Inclusion age: All ages Level of evidence: IV
Fracheboud, 1998^23^ Country: Netherlands Design: Retrospective cohort Time Period: 1990–1995 | Recruitment: Dutch nation-wide screening program Sampling: Not random Applicability: Some women were lost to followup due to women's delay, priority given to other diseases, a move to another region or country, insufficient feedback by specialists and referrals among women who refused registration; some women who were invited to the program chose not to be screened | Definition: DCIS Diagnosis: Mammography Validation: Biopsy | Sample size: 1,000 Length of followup: 6 years Range: N/S-N/S Loss of followup: 0.02 Inclusion age: ≥ 49 Level of evidence: II-2C
Kitchen, 1998^24^ Country: Australia Design: Retrospective cohort Time Period: 1993–1996 | Recruitment: City and North-Eastern Breast Screen of Breast Screen Australia Sampling: Not random Applicability: Six screening centers (4 urban, 1 rural mobile, and 1 fixed provincial) may not have provided an accurate representation of breast cancer | Definition: DCIS Diagnosis: Mammography Validation: Further imaging, clinical examination by a surgeon, fine needle aspiration cytology and core-biopsy | Sample size: 52,126 Length of followup: 32 months Range: N/S-N/S Loss of followup: N/A Inclusion age: >40 Level of evidence: II-2C
Warren, 1999^25^ Country: UK Design: Retrospective cohort Time Period: 1987–1996 | Recruitment: UK National breast screening program Registry Applicability: N/S | Definition: Not specified Diagnosis: Mammography Validation: Not specified | Sample size: 33,734 Length of followup: 120 months Range: N/S-N/S Loss of followup: 0.25 Inclusion age: 40–64 Level of evidence: II-2C
Barchielli, 1999^26^ Country: Italy Design: Retrospective cohort Time Period: 1985–1995 | Recruitment: Tuscany cancer registry Registry: All sampled Applicability: Lower amount of women who participated in mammographic screening; only generalizable within Florence, Italy; women participating in mammography screening were recruited by personal invitation, self- referrals or were assessed because of breast symptoms or a period check up after a breast cancer | Definition: DCIS Diagnosis: Mammography Validation: Positive cyto-histologic referrals collected from public and private pathology services | Sample size: 100,000 Length of followup: 10 years Range: N/S-N/S Loss of followup: N/A Inclusion age: All ages Level of evidence: II-2C
Kerlikowski, 2000^27^ Country: USA Design: Retrospective cohort Time Period: April 1985–November 1997 | Recruitment: 7 registries participating in the National Cancer Institute Breast Cancer Surveillance Consortium - San Francisco Mammography Registry (San Francisco, CA), Group Health Cooperative (Seattle, WA), Fred Hutchinson Cancer Research Center (Seattle, WA), New Mexico Mammography Project (Albuquerque, NM), Vermont Mammography Registry (Burlington, VT), Colorado Mammography Advocacy Project (Denver, CO), New Hampshire Mammography Network (Hanover, NH) Registry; All sampled Applicability: Cancer reporting to the SEER program, state tumor registries, and the pathology laboratories used by the mammography registries may be incomplete, registries limit data collection to residents of a defined region | Definition: DCIS Diagnosis: Mammography Validation: Excisional and core biopsies | Sample size: 389,533 Length of followup: 12 years and 7 months Range: N/S-N/S Loss of followup: N/A Inclusion age: 30–69 Level of evidence: II-2B
Walter, 2001^28^ Country: USA Design: Prospective cohort Time Period: 1995–1999 | Recruitment: On Lok, a long-term care delivery system available to frail community-dwelling elderly persons living San Francisco Sampling: Not random Applicability: Women were excluded if their mammography was not considered a screening exam (screening is defined as an exam performed on an asymptomatic woman) | Definition: DCIS Diagnosis: Mammography Validation: Biopsy | Sample size: 216 Length of followup: 4 years and 9 months or 2 years and 10 months depending on time of enrollment Range: N/S-N/S Loss of followup: N/A Inclusion age: ≥ 55 Level of evidence: IV
Innos, 2002^29^ Country: USA Design: Retrospective cohort Time Period: 1988–1999 | Recruitment: California Cancer Registry Registry: All sampled Applicability: Nongeneralizable to women not living in California or less than 40 years of age | Definition: All cases of carcinoma in situ in the breast, excluding lobular carcinoma in situ, but including noninfiltrating intraductal carcinoma, comedocarcinoma, intraductal papillary adenocarcinoma, intraductal carcinoma with lobular carcinoma in situ and other specific or nonspecific histologic types Diagnosis: N/S Validation: Case reports | Sample size: 100,000 Length of followup: 11 years Range: N/S-N/S Loss of followup: N/A Inclusion age: ≥ 40 Level of evidence: II-2C
Ernster, 2002^30^ Country: USA Design: Retrospective cohort Time Period: 1996–1997 | Recruitment: Breast Cancer Surveillance Consortium mammography registries located in Colorado, New Hampshire, New Mexico, North Carolina, San Francisco (CA), Vermont and western Washington State Registry: All sampled Applicability: Women were included if their mammography examination was designated as a screening mammogram and not a diagnostic examination by the radiologist; unilateral screening examinations and examinations that did not have an assessment code indicating whether they had been considered negative or positive for an abnormality indicative of cancer were excluded, women who had any breast imaging in the preceding 9 months were excluded because imaging within this period may indicate that the screening mammographic examination was not a true screening examination but rather a followup examination; other cases of in situ lesions were considered DCIS even if they were not; not all mammography facilities in a particular region are included in the BCSC for that region Race: 86% of women self-reported race = 79% White, 5% African-American, 2% Asian/Pacific Islander, 2% Native American, 12% were other/mixed; 81% of women responded to the question about whether they were of Hispanic origin = 4% reported being Hispanic | Definition: DCIS (LCIS were excluded, but other cases of in situ lesions were included) Diagnosis: Mammography Validation: Cancer registry or pathology registry data | Sample size: 540,738 Length of followup: 2 years Range: N/S-N/S Loss of followup: N/A Inclusion age: 40–84 Level of evidence: II-2C
Schootman, 2003^31^ Country: USA Design: Retrospective cohort Time Period: 1973–1997 | Recruitment: SEER registries of Iowa, New Mexico, and Utah Registry: All sampled Applicability: Dichotomization of populations into either urban or rural; included only registries that contained both rural and urban counties Race: 8.0% African Americans, 0.5% Hispanic | Definition: DCIS according to the following morphology codes: 85002, 85012, 80502, 82012, 85032, 85042, 85222, 85433 Diagnosis: N/S Validation: Medical records at hospitals and outpatient facilities in all urban and rural areas covered by the registries | Sample size: N/S Length of followup: 24 years Range: N/S-N/S Loss of followup: N/A Inclusion age: 50–69 Level of evidence: II-2C
Smith, 2003^32^ Country: USA Design: Retrospective cohort Time Period: 1996–1999 | Recruitment: Breast Cancer Surveillance Consortium consisting of mammography registries from San Francisco, California; Colorado; New Hampshire; New Mexico; North Carolina; Seattle, Washington; Vermont Registry: All sampled Applicability: Women included are self-referred or are referred by a physician; cancers that occurred after a mammogram with negative findings were excluded | Definition: Referred to as "in situ" throughout the paper but in the abstract section under "Design, Setting and Participants", refers to women included in the study as diagnosed with breast cancer: invasive or ductal carcinoma in situ Diagnosis: Mammography Validation: Medical records | Sample size: 978,591 Length of followup: 4 years Range: N/S-N/S Loss of followup: N/A Inclusion age: ≥ 50 Level of evidence: IV
Baxter, 2004^33^ Country: USA Design: Retrospective cohort Time Period: 1992–1999 | Recruitment: SEER Registry (11 population-based cancer registries and 3 supplemental registries that were added to SEER in January 1992) Registry: All sampled Applicability: Limited information on patient and tumor characteristics; no information on any use of hormonal therapy; no information on mode of detection, the presence of multifocal disease, or margin status, individual provider practice patterns may vary among each other | Definition: DCIS with no evidence of microinvasion Diagnosis: N/S Validation: Microscopic confirmation | Sample size: 100,000 Length of followup: 7 years Range: N/S-N/S Loss of followup: N/A Inclusion age: >18 Level of evidence: II-2C
Coburn, 2004^34^ Country: USA Design: Retrospective cohort Time Period: 1987–2001 | Recruitment: Rhode Island Cancer Registry Registry: All sampled Applicability: Non-generalizable to women living anywhere other than Rhode Island; population likely to have the lowest rates of mammography screening are also least likely to be included in the survey due to communication difficulties or lack of telephone | Definition: DCIS Diagnosis: Mammogram Validation: Pathology reports | Sample size: 100,000 Length of followup: 2 years Range: N/S-N/S Loss of followup: N/A Inclusion age: All ages Level of evidence: I
Anderson, 2004^35^ Country: USA Design: Retrospective cohort Time Period: 1973–2000 | Recruitment: SEER registries: Connecticut, Hawaii, Iowa, Utah, New Mexico; metropolitan areas of San Francisco, Detroit, Atlanta, and Seattle-Puget Sound Registry: All sampled Applicability: Some missing data on method of detection Race: 82% white, 9% African American, 9% other, <1% unknown | Definition: DCIS non-comedo Diagnosis: N/S Validation: Not specified | Sample size: 100,000 Length of followup: 29 years Range: N/S-N/S Loss of followup: N/A Inclusion age: All ages Level of evidence: IV
Fracheboud, 2004^36^ Country: Netherlands Design: Retrospective cohort Time Period: 1989–1997 | Recruitment: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Registry: All sampled Applicability: Case ascertainment by the registry is higher than 95% but some cases are not detected | Definition: DCIS Diagnosis: Mammography Validation: Biopsy | Sample size: 100,000 Length of followup: 9 years Range: N/S-N/S Loss of followup: N/A Inclusion age: All ages Level of evidence: II-2C
Erbas, 2004^37^ Country: Australia Design: Retrospective cohort Time Period: 1993–2000 | Recruitment: Breast Screen Victoria Sampling: Not random Applicability: Women ages <50 and >75 years are not routinely invited to attend; selection bias among older women choosing to attend the screening program | Definition: DCIS Diagnosis: Mammography Validation: Not specified | Sample size: 1,000 Length of followup: 8 years Range: N/S-N/S Loss of followup: N/A Inclusion age: ≥ 40 Level of evidence: I
Kricker, 2004^38^ Country: Australia Design: Retrospective cohort Time Period: 1995–2000 | Recruitment: New South Wales Central Cancer Registry Registry: All sampled Applicability: N/S | Definition: DCIS Diagnosis: Mammography Validation: Pathology reports | Sample size: 100,000 Length of followup: 6 years Range: N/S-N/S Loss of followup: 0.04 Inclusion age: All ages Level of evidence: II-2C
Barchielli, 2005^39^ Country: Italy Design: Retrospective Cohort Time Period: 1988–1999 | Recruitment: Italian cancer registry and screening programs Registry Applicability: N/S | Definition: DCIS Diagnosis: Pre-screening Validation: Not specified | Sample size: Not specified Length of followup: 34 months Range: N/S-N/S Loss of followup: N/A Inclusion age: 40–79 Level of evidence: II-2C
Blanks, 2005^40^ Country: England Design: Controlled, comparative, observational study of the NHS breast screening programs in England Time Period: April 2001–March 2003. | Recruitment: The National health Service Breast Screening Program Sampling: Random Applicability: N/S | Definition: DCIS Diagnosis: Two-view Mammography Validation: Not specified | Sample size: 531,203 Length of followup: 24 months Range: N/S-N/S Loss of followup: N/A Inclusion age: 50–64 Level of evidence: I
Leach, 2005^41^ Country: UK Design: Prospective Cohort Time Period: 1997–2004 | Recruitment: Magnetic Resonance Imaging Breast Screening study Sampling: Not random Applicability: Many women chose to be excluded from the study for various reasons; some women who agreed to participate in the study were excluded due to logistical problems; some women were screened with only one technique and were excluded; women at high risk of breast cancer were chosen to be in the study | Definition: DCIS (alone) Diagnosis: Mammography and contrast enhanced breast magnetic resonance imaging Validation: Biopsy/pathology | Sample size: 649 Length of followup: 81 months Range: N/S-N/S Loss of followup: N/A Inclusion age: 35–49 (actual age of subjects was 31–55) Level of evidence: II-2A
Birdwell, 2005^42^ Country: USA Design: Prospective cohort Time Period: 2001–2002 | Recruitment: Stanford University Medical Center Sampling: Not random Applicability: Generalizable only to women who go to that particular hospital; 13 women were lost to followup; the study was not designed for followup of patients into the next screening interval | Definition: DCIS Diagnosis: Mammogram (using two different mammography systems) and a computer-aided detection (CAD) system Validation: Biopsy (fine-needle aspiration, core, excisional) | Sample size: 8,682 Length of followup: 19 months Range: N/S-N/S Loss of followup: N/A Inclusion age: All ages Level of evidence: II-2C
Kumar, 2005^43^, Additional analysis of the sample reported in Li, 2005 44 Country: USA Design: Retrospective cohort Time Period: 1980–2002 | Recruitment: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, Seattle-Puget Sound Registry: All sampled Applicability: Study includes higher proportions of people living in urban areas and higher proportions of people who are foreign born; data does not capture atypical ductal hyperplasia | Definition: DCIS Diagnosis: N/S Validation: Not specified | Sample size: 100,000 Length of followup: 22 years Range: N/S-N/S Loss of followup: N/A Inclusion age: N/S Level of evidence: II-2B
Smith-Bindman, 2005^45^ Country: USA Design: Retrospective cohort Time Period: 1996–1999 | Recruitment: Breast Cancer Surveillance Consortium with mammography registries in San Francisco (California), Colorado, New Hampshire, New Mexico, North Carolina, Western Washington and Vermont Registry: All sampled Applicability: Subjects are ascertained in certain geographical locations within the U.S. | Definition: DCIS Diagnosis: Mammogram Validation: Pathology database or tumor registry | Sample size: 1,000 Length of followup: 3 years Range: N/S-N/S Loss of followup: N/A Inclusion age: ≥50 Level of evidence: II-2C
Li, 2005^44^ Country: USA Design: Retrospective cohort Time Period: 1980–2001 | Recruitment: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, Seattle-Puget Sound Registry: All sampled Applicability: Study includes higher proportions of people living in urban areas and higher proportions of people who are foreign born; data does not capture atypical ductal hyperplasia | Definition: DCIS (comedo and noncomedo) Diagnosis: Individual patient records Validation: Not specified | Sample size: 100,000 Length of followup: 22 years Range: N/S-N/S Loss of followup: N/A Inclusion age: ≥30 Level of evidence: II-2C
Weaver, 2005^46^ Country: USA Design: Retrospective cohort Time Period: 1997–2001 | Recruitment: Vermont Breast Cancer Surveillance System Registry: All sampled Applicability: Women were excluded it there was no record of mammography within the year before the biopsy, women were also excluded if they were diagnosed with breast cancer before 1997; women were only included if they had undergone a biopsy | Definition: DCIS Diagnosis: Mammography Validation: Biopsy | Sample size: 7,670 Length of followup: 5 years Range: N/S-N/S Loss of followup: N/A Inclusion age: ≥18 Level of evidence: II-2C
Kerlikowski, 2005^47^ Country: USA Design: Retrospective cohort Time Period: January 1986-December 2001 | Recruitment: San Francisco Mammography Registry Registry: All sampled Applicability: Women who had a prior breast cancer diagnosis, breast augmentation, reduction or reconstruction, or history of mastectomy were excluded Race: 64% non-Hispanic white, 28% Chinese, 8% Filipino | Definition: DCIS Diagnosis: Mammography Validation: Biopsy | Sample size: 103,259 Length of followup: 6 years Range: N/S-N/S Loss of followup: N/A Inclusion age: ≥40 Level of evidence: II-2C
Duffy, 2005^48^ Country: Sweden Design: Randomized controlled clinical trial Time Period: 1978–1986 | Recruitment: Swedish Two-Country Trial Sampling: Random Applicability: N/S | Definition: DCIS Diagnosis: Mammography Validation: Clinical or pathologic records | Sample size: 1,000 Length of followup: 8 years Range: N/S-N/S Loss of followup: N/A Inclusion age: 40–74 Level of evidence: I
Nakhlyudov, 2006^49^ Country: USA Design: Retrospective cohort Time Period: 1992–2000 | Recruitment: The Department of Ambulatory Care and Prevention, the Nurses’ Health Study 121,700 female registered nurses age 30 to 55 were enrolled in 1976; 116,671 female registered nurses age 25 to 42. Were enrolled in 1989. Exclusion: 269 women with DCIS who did not complete the pre-DCIS surveys immediately before being diagnosed 185 women with DCIS, invasive breast cancer, or other cancer except nonmelanoma skin cancer before the initial survey, 5 women whose DCIS diagnosis indicated the presence of lobular and/or invasive characteristics, 2 women diagnosed during 1996 to 2000 who did not respond to the main NHS survey and had missing information on key patient characteristics, 17 women who reported receiving chemotherapy, which is not a standard treatment option for women with DCIS, 4 women who died before completing the followup (post-DCIS) functional assessment were excluded Applicability: Female nurses in the US | Definition: DCIS Diagnosis: mammography Validation: Not specified | Sample size: 114,728 Length of followup: 48 months Range: N/S-N/S Loss of followup: N/A Inclusion age: Not specified Level of evidence: II-2C
Boncz, 2006^50^ Country: Hungary Design: Retrospective cohort Time Period: 2002–2003 | Recruitment: Hungarian Breast Cancer Screening Program Registry: All sampled Applicability: Generalizable only to women targeted in the breast screening program and to women within Hungary; women were excluded if they had a mammography examination in the previous 2 years; women were recruited through mail | Definition: DCIS Diagnosis: Mammogram (independently reviewed by two radiologists) Validation: Further diagnostic assessment (including ultrasound examination, needle biopsy, cytology-histology, etc) | Sample size: 531,244 Length of followup: 2 years Range: N/S-N/S Loss of followup: N/A Inclusion age: 45–65 Level of evidence: II-2C
Gill, 2006^51^ Country: USA Design: Case control Time Period: 1993–2000 | Recruitment: Hawaii component of the Multiethnic Cohort Registry: All sampled Applicability: Cannot rule out bias towards the null in estimates of DCIS risk because of the possibility of undetected breast DCIS among controls, low participation rates, limited power to estimate DCIS | Definition: DCIS Diagnosis: Mammogram Validation: N/S | Sample size: 1,268 Length of followup: 5–8 years Range: N/S-N/S Loss of followup: N/A Inclusion age: All ages Level of evidence: II-3
Weaver, 2006^52^ Country: USA Design: Retrospective cohort Time Period: 1996–2001 | Recruitment: Breast Cancer Surveillance Consortium - only the 5 registries that collect both pathology data and cancer registry data were included Registry: All sampled Applicability: Biopsy results that were performed outside of the catchment area of the registries were not collected | Definition: DCIS Diagnosis: Mammogram Validation: Pathology reports | Sample size: 1,664,032 Length of followup: 5 years Range: N/S-N/S Loss of followup: N/A Inclusion age: 40–89 Level of evidence: II-2C
Rakovitch, 2006^53^ Country: Canada Design: Retrospective cohort Time Period: 1991–2000 | Recruitment: Ontario Breast Screening Program Sampling: Not random Applicability: Women over 50 were targeted for the study; generalizability of the study is unknown | Definition: DCIS (no microinvasion or bilateral DCIS) Diagnosis: N/S Validation: Pathology reports | Sample size: 13,529 Length of followup: 10 years Range: N/S-N/S Loss of followup: N/A Inclusion age: ≥50 Level of evidence: II-2C
Yeoh, 2006^54^ Country: Singapore Design: Retrospective cohort Time Period: 2002–2004 | Recruitment: National Breast Screening Program, Breast Screen Singapore Sampling: Not random Applicability: Participation rates in the program are relatively low | Definition: DCIS Diagnosis: Mammogram Validation: Not specified | Sample size: 84,000 Length of followup: N/S Range: N/S-N/S Loss of followup: N/A Inclusion age: ≥40 Level of evidence: II-2C
Moran, 2006^55^ Country: Ireland Design: Prospective cohort Time Period: 2002–2003 | Recruitment: Screening unit located in Dublin, Ireland Sampling: Not random Applicability: The study was single-institutional so therefore may not be generalizable; there was a relatively short followup period in the study | Definition: DCIS Diagnosis: Mammogram Validation: Stereotactic core biopsy | Sample size: 24,426 Length of followup: 2 years Range: N/S-N/S Loss of followup: N/A Inclusion age: 50–65 Level of evidence: IV
Sumner, 2007^56^ Country: USA Design: Retrospective cohort Time Period: 1981–2001 | Recruitment: Florida Cancer Data System Registry Applicability: N/S Race: 85% White, 6.6% African American, 7.5% Hispanic | Definition: DCIS Diagnosis: Mammography Validation: Not specified | Sample size: N/S Length of followup: 240 months Range: N/S-N/S Loss of followup: N/A Inclusion age: 18–103 Level of evidence: II-2C
Rakovitch, 2007^53^ Country: Canada Design: Retrospective cohort Time Period: 1991–2000. | Recruitment: Ontario Breast Screening Program All sampled Applicability: N/S | Definition: DCIS Diagnosis: Mammography Validation: Not specified | Sample size: 13,529 Length of followup: 10years Range: N/S-N/S Loss of followup: N/A Inclusion age: 49–87 Level of evidence: II-2C
Kerlikowski, 2007^57^ Country: USA Design: Prospective cohort Time Period: 1997–2004 | Recruitment: 4 Breast Cancer Surveillance Consortium mammography registries: San Francisco Mammography Registry, Group Health's Breast Cancer Surveillance Project, Vermont Breast Cancer Surveillance System, and New Hampshire Mammography Network Registry: All sampled Applicability: Women included in the sample had a prior mammography examination within 9–30 months preceding their first screening examination in the study | Definition: DCIS Diagnosis: Mammogram Validation: Pathology reports (not reported in this paper) | Sample size: 232,212 Length of followup: 8 years Range: N/S-N/S Loss of followup: N/A Inclusion age: 50–69 Level of evidence: II-2C
MacKenzie, 2007^58^ Country: USA Design: Prospective cohort Time Period: 1994–2001 | Recruitment: New Hampshire mammography registry Registry: All sampled Applicability: Women were required to have at least 60 days of followup in the registry, women with a personal history of breast cancer, breast implants, or breast reduction surgery were excluded; the study was based on an open cohort so women entered the registry and became eligible for analysis at different points of time so there is a possibility that DCIS was overlooked in some women. | Definition: DCIS (according to SNOMED or TNM codes) Diagnosis: Mammography Validation: Pathology diagnoses | Sample size: 75,798 Length of followup: 8 years Range: N/S-N/S Loss of followup: N/A Inclusion age: ≥40 Level of evidence: II-2C
Kerlikowski, 2007^59^ Country: USA Design: Prospective cohort Time Period: 1993–2003 | Recruitment: Breast Cancer Surveillance Consortium: San Francisco Mammography Registry, Group Health's Breast Cancer Surveillance, Colorado Mammography Advocacy Project, Vermont Breast Cancer Surveillance System, New Hampshire Mammography Network, Carolina Mammography Registry, New Mexico Mammography Registry Registry: All sampled Applicability: Women included had to have had two screening mammography examinations within the study period that were more than 9 months apart; women who were using postmenopausal hormone therapy were excluded; women who were of invalid age or had incomplete cancer diagnosis information were excluded Race: In women with no breast cancer (n=299,316): 80.6% White, 9.1% African American, 5.2% Hispanic, 3.4% Asian/Native Hawaiian/Pacific Islander, 0.5% American Indian/Alaskan native, 1.1% were other/mixed races; women with breast cancer (n=2,639: 84.2% White, 9.2% African American, 2.5% Hispanic, 2.5% Asian/Native Hawaiian/Pacific Islander, 0.4% American Indian/Alaskan native, 1.2% were other/mixed races. | Definition: DCIS Diagnosis: Mammography Validation: Medical report | Sample size: 301,955 Length of followup: 11 years Range: N/S-N/S Loss of followup: N/A Inclusion age: ≥30 Level of evidence: II-2C
Tuncbilek, 2007^60^ Country: Turkey Design: Retrospective cohort Time Period: 2005 | Recruitment: Department of Radiology, Gazi University School of Medicine, Ankara, Turkey Sampling: Not random Applicability: Women were referred from clinics by physicians who were asked to report a detailed clinical breast examination | Definition: DCIS Diagnosis: Mammogram Validation: Biopsy, pathology database, patient files | Sample size: 648 Length of followup: 1 year Range: N/S-N/S Loss of followup: N/A Inclusion age: All ages Level of evidence: II-2C
Hofvind, 2008 61 Country: Norway Design: Retrospective cohort Time Period: 1996–2004 | Recruitment: The Norwegian Breast Cancer Screening Program Registry Applicability: N/S | Definition: DCIS Diagnosis: Screening program Validation: Not specified | Sample size: Not specified Length of followup: 12 years Range: N/S-N/S Loss of followup: N/A Inclusion age: 50–69 Level of evidence: II-2C
Yu, 2008^62^ Country: USA Design: Retrospective cohort Time Period: 1999–2006 | Recruitment: Memorial Sloan-Kettering Cancer Center Sampling: Not random Applicability: Enrollment into the surveillance program was based on either patient or physician referral, patients were excluded if they were diagnosed with cancer within 6 months of enrollment, patients with a history of atypical duct hyperplasia or LCIS were excluded, all study participants had a family history of breast and/or ovarian cancer and at least 1 year followup. | Definition: DCIS Diagnosis: Biannual clinical breast examination and annual screening mammography, optional MRI screening Validation: Ultrasound. Biopsy | Sample size: 1,019 Length of followup: 7 years and 3 months Range: 1–7.3 Loss of followup: N/A Inclusion age: All ages Level of evidence: II-2C
Vigeland, 2008^63^ Country: Norway Design: Retrospective cohort Time Period: 2004–2005 | Recruitment: Norwegian Breast Cancer Screening Program Sampling: Not random Applicability: Variability among radiologists among 18 counties | Definition: DCIS Diagnosis: Mammogram, ultrasound, clinical examination Validation: Core needle biopsy or fine-needle aspiration | Sample size: 18,239 Length of followup: 23 months Range: N/S-N/S Loss of followup: N/A Inclusion age: 50–69 Level of evidence: I

Table F2 Original epidemiologic studies of risk factors for DCIS

Study | Patients | Definition of DCIS and Control for Bias
Weiss, 1996^64^ Country: USA Design: Case control Evidence: II-2B Time Period: May 1, 1990- December 31, 1992 Length of followup/months: N/A | Data source: Cancer registry in Atlanta, Georgia, Seattle/Puget Sound, Washington, and central New Jersey Inclusion criteria: Breast cancer patients 20–44 years old diagnosed during the period of May 1, 1990, through December 31, 1992 identified in cancer registry in Atlanta, Georgia, Seattle/Puget Sound, Washington, and central New Jersey. Population based controls were identified by random-digit dialing among the residents of the same states. Exclusion: Not having residential phone number Inclusion Age: 20–44 Mean age: NR Sample size: 3,152 | Definition: DCIS identified in cancer registry with histological confirmation in SEER database or hospital records in New Jersey Masking of outcome assessment: Not reported Control for bias: Adjusted for age at diagnosis, study site, smoking, number of mammographs in 5 year period, family history of breast cancer, race, parity, and BMI
Kerlikowske, 1997^65^ Country: USA Design: Cross-sectional Evidence: II-2B Time Period: April 1985 - September 1995 Length of followup/months: 1 | Data source: University of California San Francisco Mobile Mammography Screening Program Inclusion criteria: All 39,542 women aged 30 years and older who underwent a screening mammographic examination at the University of California San Francisco Mobile Mammography Screening Program in April 1985 – September 1995 who had her records linked to the regional Surveillance, Epidemiology, and End Results cancer registry Exclusion: History of breast cancer or mastectomy Inclusion Age: >30 Mean age: Sample size: 39,542 | Definition: DCIS identified after biopsy Masking of outcome assessment: Not reported Control for bias: Adjusted for age, age at first birth, family history of breast cancer, age at menarche, BMI, parity, and previous breast surgery
Elmore, 1998^66^ Country: USA Design: Well-designed nested case-control study (retrospective cohort) Evidence: II-2C Time Period: 1985–1993 Length of followup/months: 96 | Data source: Yale-New Haven Hospital Tumor Registry Inclusion criteria: All Black female patients of all ages with a first diagnosis of breast carcinoma verified by tissue pathology at Yale-New Haven Hospital from January 1, 1985-December 31, 1993, were selected from the hospital tumor registry. White control patients with breast carcinoma were selected randomly and matched to each black patient by the year of breast carcinoma diagnosis in a 3:1ratio. Exclusion: From medical records for 120 black and 346 white patients were reviewed; 20 black patients were excluded (6 had a history of breast carcinoma prior to January 1, 1985, 1 did not have breast carcinoma, 1 had an incorrect race designated, and 12 were duplicate names). 46 white patients were excluded (32 had breast carcinoma prior to January 1, 1985, 1 had no evidence of breast carcinoma, 6 had an incorrect race designated, 1 had inadequate records, and 6 were duplicate names). Inclusion Age: N/S Mean age: N/S Sample size: 400 | Definition: DCIS recorded as a medical diagnosis in Tumor registry Masking of outcome assessment: Not reported Control for bias: Adjusted for race, age, insurance status, income, and method of detection (screening mammogram, clinical breast examination, patient noted)
Elkhadrawy, 1998^67^ Country: USA Design: Case control study Evidence: IIB Time Period: January 1, 1989 - December 31, 1993 Length of followup/months: N/A | Data source: Columbia Presbyterian Medical Center (CPMC) Inclusion criteria: All cases of female DCIS registered in CPMC cancer registry between January 1, 1989 and December 31, 1993. Controls were randomly selected females who underwent surgery for different benign conditions that are not associated with serum cholesterol at CPMC at the same time. Exclusion: N/S Inclusion Age: NS Mean age: 58.6 Sample size: 394 | Definition: DCIS Masking of outcome assessment: Not reported Control for bias: Adjusted for age, serum cholesterol, serum albumin, menopausal status
Bohlke, 1998^68^ Country: USA Design: Case control study Evidence: IIB Time Period: January 1, 1993- August 30, 1997 Length of followup/months: 18.5 | Data source: the Massachusetts Cancer Registry Inclusion criteria: DCIS cases diagnosed between January 1, 1993, and August 30, 1997, through the Massachusetts Cancer Registry, younger than 50 years, residing in eastern Massachusetts, premenopausal. Controls were randomly selected from annually published Massachusetts town lists. 94 cases with DCIS and 76 controls were included Exclusion: Pregnancy, breastfeeding, taking exogenous hormones during the preceding 3 months, chemotherapy or radiation to the pelvis Inclusion Age: <50 Mean age: NR Sample size: 170 | Definition: DCIS Masking of outcome assessment: Not reported Control for bias: Matching controls to cases by age (within 2 years) and precinct of residence. Adjustment for age (years), ethnic group (white, black, Hispanic, Asian), body mass index [weight (kg) per height squared (m2)], height (cm), parity (parous, nulliparous), age at menarche (years), age at first birth (years; among parous women), first-degree family history of breast cancer (present, absent), and estradiol level (pg per ml).
Gapstur, 1999^69^ Country: USA Design: Prospective cohort study Evidence: II-2A Time Period: January 1986 - December 1996 Length of followup/months: 132 | Data source: The Iowa Women’s Health Study Inclusion criteria: The Iowa Women’s Health Study is a prospective cohort study designed to examine the effect of several risk factors on the incidence of cancer in postmenopausal women aged 55 to 69 years at baseline. Randomly selected from the 1985 Iowa Department of Transportation driver’s license list (94% of all Iowa women) were invited in January 1986 to participate, 42% from 98,029 eligible women responded and consented. Exclusion: Women with low risk of breast cancer who at baseline (1) were premenopausal (n = 569), (2) reported a previous total or partial mastectomy (n = 1870), or (3) reported a personal history of non skin cancer (n = 2293). Inclusion Age: 55-69 Mean age: Sample size: 37,105 | Definition: DCIS identified using the Health Registry of Iowa, part of the National Cancer Institute’s Surveillance, Epidemiology and End Results program Masking of outcome assessment: Not reported Control for bias: Adjusted for age (continuous variable), body mass index, body mass index at age 18 years, waist-to-hip ratio, age at menarche, age at menopause, age at first birth, parity, family history of breast cancer in a first-degree relative, type of menopause, and alcohol intake using Cox proportional hazards regression
Trentham-Dietz, 2000^70^ Country: USA Design: Case control study Evidence: II-3 Time Period: 1988–1990 Length of followup/months: N/A | Data source: Wisconsin’s mandatory cancer registry Inclusion criteria: All female residents of Wisconsin with a new diagnosis of in situ or invasive breast cancer who were 75 years of age. Cases were identified by Wisconsin’s mandatory cancer registry (fifth digit behavior code=2; 8500, 8501, 8503, 8504, 8010, and 8140) from April 1988-December 1990. Eligibility was limited to cases with listed telephone numbers and known dates of diagnosis. The data for 301 in situ cases (85%) were available for analysis. Community controls were randomly selected from two sampling frames: those under age 65 years were selected from a list of licensed drivers, and controls ages 65–75 years were selected from a roster of Medicare beneficiaries compiled by the Health Care Financing Administration. Computer files of potential controls were obtained annually. Controls had no previous diagnosis of breast cancer, listed telephone number. Of the 4,445 potential controls, 49 (1%) were deceased, 21 (<1%) could not be located, and 376 (9%) refused to participate. The overall response rate for control subjects was 90% (n =3,999). Exclusion: 65 years of age without a driver’s license (by self- report) Inclusion Age: 18–74, Mean age: N/S Sample size: 3,999 | Definition: Ductal/nonlobular carcinoma (ICD codes 8500, 8501, 8503, 8504, 8010, and 8140) Masking of outcome assessment: Not reported Control for bias: Adjusted for age, age at first birth, family history of breast cancer, age at menopause, and education.
Claus, 2001^71^ Country: USA Design: Case control study Evidence: IIB Time Period: September 15, 1994-March 14, 1998 Length of followup/months: N/A | Data source: Rapid-case-ascertainment shared resource of the Yale Cancer Center (Yale University, New Haven, CT) Inclusion criteria: All case patients with DCIS or LCIS ages 20–79 years at the time of diagnosis diagnosed among female residents of Connecticut from September 15, 1994, through March 14, 1998. Controls were female Connecticut residents selected by random-digit dialing methods by an outside consulting firm (Northeast Research, Oreno, ME).The final study population included 1,068 case patients and 999 control subjects, with overall estimated response rates of 76% and 70% for case patients and control subjects Exclusion: Out-of-state residency,(8 patients), non-English speaking (21 patients), history of breast cancer/biopsy of unknown outcome (181 patients), age older than 79 years (31 patients), mixed histology (DCIS+LCIS) Inclusion Age: NS Mean age: 56.6 ± 11.4 Sample size: 1,874 | Definition: DCIS Masking of outcome assessment: Not reported Control for bias: Adjusted for age (continuous), college education (yes/no), history of at least one screening mammogram 1 year before interview, body mass index, and ethnicity (white/other), age at menarche, previous breast biopsy, family history of breast cancer, parity, age at first live birth, age at menopause, external hormone use, ever smoke, and ever drink
Cuzick, 2002^72^ Country: UK, Australia, New Zealand Design: randomized controlled clinical trial Evidence: I Time Period: 1992–2001 Length of followup/months: 50 | Data source: IBIS (International Breast Cancer Intervention Study) center Inclusion criteria: Women ages 35–70 years with risk factors for breast cancer indicating at least a twofold relative risk if they were 45–70 years of age, a fourfold relative risk if they were 40–44 years of age, or a 10- fold relative risk if they were 35–39 years of age. Women were eligible from age 45 years if they had 1) a mother or sister diagnosed with breast cancer before the age of 50 years, 2) two first- or second-degree relatives with breast cancer at any age, or 3) a first-degree relative with breast cancer at any age, and either were nulliparous or had a previous hyperplastic benign lesion. Women were eligible from the age of 40 years if they had 1) atypical ductal or lobular hyperplasia, 2) a first first-degree relative with bilateral breast cancer at any age, or 3) two first- or second- degree relatives with breast cancer, one of whom was diagnosed before age 50 years. Women were eligible from the age of 35 years if they had either 1) lobular carcinoma in situ or 2) two first first-degree relatives with breast cancer, both diagnosed before the age of 50 years. Any women with an estimated 10-year risk of 5% or more were also eligible as risk equivalent after approval by the study chairman. Exclusion: Any previous invasive cancer (except non- melanoma skin cancer), a previous deep-vein thrombosis or pulmonary embolism, current use of anticoagulants, or a life expectancy judged to be <10 years, present or planned pregnancy. Inclusion Age: 35–70 Mean age: 50.7 Sample size: 7,152 | Definition: DCIS Masking of outcome assessment: Double blind Control for bias: Intention to treat, after exclusion of the 13 women found to have breast cancer at baseline The mean age was 50.8 years (SD 6.9); 54.7% of the women were between the ages of 45 and 54 ; 49% were postmenopausal and 41% had previously used hormone- replacement therapy.
Frank, 2002^73^ Country: USA Design: Retrospective cohort Evidence: II-2C Time Period: 1996–1999 Length of followup/months: 36 | Data source: Myriad Genetic Laboratories and Myriad Genetics, Inc, Salt Lake City, UT. Inclusion criteria: Retrospective study of consecutive tests performed in a clinical setting in 10,000 individuals analyzed by Myriad Genetic Laboratories over a 3-year period. 7,461 were analyzed for the coding sequences of BRCA1 and BRCA2 and 2,539 analyzed only for three specific founder mutations prevalent in individuals of Ashkenazi Jewish ancestry. Exclusion: Non completed by health care provider information to specify the ancestry of the proband, the family history (including breast, ovarian, and other cancers, age of diagnosis, and relationship to patient), whether the proband had not been diagnosed with cancer, or whether there was a history of breast, ovarian, or other cancers, including the age of diagnosis of each. Inclusion Age: 18–96 Mean age: 49 (median) Sample size: 9,090 | Definition: DCIS Masking of outcome assessment: Not reported Control for bias: Age and family history
Johnson, 2002^74^ Country: USA Design: Prospective cohort study Evidence: IIA Time Period: 1992-December 31, 1999 Length of followup/months: 72 | Data source: The Iowa Women’s Health Study cohort. Breast cancer incidence was ascertained by linkage to the State Health Registry of Iowa, which is part of the National Cancer Institute’s Surveillance, Epidemiology, and End Results Program Inclusion criteria: The Iowa Women’s Health Study is a prospective cohort study designed to examine the effect of several risk factors on the incidence of cancer in postmenopausal women ages 55 to 69 years at baseline. Randomly selected from the 1985 Iowa Department of Transportation driver’s license list (94% of all Iowa women) were invited in January 1986 to participate, 42% from 98,029 eligible women responded and consented. Exclusion: Premenopausal status, cancer other than skin cancer, a previous total or partial mastectomy, lobular carcinoma in situ Inclusion Age: 55 and 69 Mean age: Sample size: 27,616 | Definition: DCIS identified in cancer registry with histological confirmation in SEER database Masking of outcome assessment: Not reported Control for bias: Adjustment for age (continuous), BMI (continuous), estrogen use (current or not current), family history of breast cancer (yes or no), benign breast disease (yes or no), multivitamin use (yes or no), mammography (yes or no), and waist: hip ratio (continuous). Aspirin analyses are adjusted for NSAIDs, and NSAID analyses are adjusted for aspirin use.
Claus, 2003^75^ Country: USA Design: Case control study Evidence: II-3 Time Period: September 15, 1994-March 14, 1998 Length of followup/months: 42 | Data source: The Rapid Case Ascertainment (RCA); Yale cancer center; Connecticut Tumor Registry Inclusion criteria: All cases of female breast carcinoma in situ between the ages of 20 and 79 years at the time of diagnosis diagnosed among residents of the state of Connecticut from September 15, 1994-March 14, 1998 identified through the Rapid Case Ascertainment (RCA) Shared Resource of the Yale Cancer Center as well as the Connecticut Tumor Registry. Controls were female Connecticut residents selected by random-digit-dialing methods by an outside consulting firm (Northeast Research) and were frequency matched by 5-year age intervals to the cases Exclusion: Previous history of breast cancer and/or a breast biopsy of unknown outcome. Cases with mixed or other pathology (i.e. both DCIS and LCIS, invasive, or no identifiable disease) Inclusion Age: 20–79 Mean age: 55 Sample size: 1,998 | Definition: DCIS, non-infiltrating identified in pathology report and confirmed via a uniform review by the study pathologist Masking of outcome assessment: Not reported Control for bias: Adjusted for age, ethnicity (white/other), family history of breast cancer (yes/no), age at first menstrual period, number of full-term pregnancies, number of screening mammograms one year prior to interview (0, 1, 2+), history of previous breast biopsy (yes/no), and a history of hormone replacement therapy (yes/no)
Claus, 2003^76^ Country: USA Design: Case control study Evidence: II-3 Time Period: September 15, 1994- March 14, 1998 Length of followup/months: 42 | Data source: The Rapid Case Ascertainment (RCA); Yale cancer center; Connecticut Tumor Registry Inclusion criteria: All women with breast carcinoma in situ between the ages of 20 and 79 years at time of diagnosis identified through the Rapid Case Ascertainment (RCA) Shared Resource of the Yale Cancer Center as well as the Connecticut Tumor Registry from September 15, 1994- March 14, 1998. Controls were randomly selected among female Connecticut residents using random-digit-dialing methods by an outside consulting firm (Northeast Research). Exclusion: Previous history of breast cancer and/or a breast biopsy of unknown outcome.1,606 cases and 1,445 controls were identified, 241 cases were ineligible due to out-of-state residency (8), language (21), a history of previous breast cancer/biopsy of unknown outcome (181) or age-group (31). 74 controls were ineligible due to out-of state residency (3), language (18), a history of previous breast cancer/biopsy of unknown outcome (51), or age-group (2). The final sample included 1,068 case and 999 control subjects, with overall response rates of 76 and 70% for cases and controls, respectively. Inclusion Age: 20–79 Mean age: 55 Sample size: 1,998 | Definition: DCIS by pathology report and confirmed via a uniform review by the study pathologist Masking of outcome assessment: Not reported Control for bias: Adjusted for age, ethnicity (white/other), family history of breast cancer (yes/no), age at first menstrual period, number of full-term pregnancies, number of screening mammograms one year prior to interview (0, 1, 2+), history of previous breast biopsy (yes/no), and a history of hormone replacement therapy(yes/no).
Kerlikowske, 2003^77^ Country: USA Design: Prospective cohort study Evidence: IIA Time Period: January 1996–December 2000 Length of followup/months: 12 | Data source: 6 mammography registries that participate in the Breast Cancer Surveillance Consortium (http://breastscreening.cancer.gov) funded by the National Cancer Institute: (1) San Francisco Mammography Registry, San Francisco, CA; (2) Group Health Cooperative, Seattle, WA; (3) Colorado Mammography Advocacy Project, Denver, CO; (4) Vermont Breast Cancer Surveillance System, Burlington, VT; (5) New Hampshire Mammography Network, Lebanon, NH; and (6) Carolina Mammography Registry, Chapel Hill, NC. Inclusion criteria: Postmenopausal women ages 50–79 years who underwent bilateral mammography examination for screening, between January 1996 and December 2000, identified in 6 mammography registries. Exclusion: Premenopausal women ages 50 to 54 years having regular menstrual periods with no HT use, self-reported breast augmentation or prior diagnosis of breast cancer, missing time between mammography examinations, family history of breast cancer, or current HT use. Lobular carcinoma-in-situ was not considered as cancer. Inclusion Age: 50–79 Sample size: 373,265 | Definition: DCIS reported in breast pathology database, SEER program, or state tumor registry; Masking of outcome assessment: Not reported Control for bias: Stratification into three groups based on self- reported current HT use and history of hysterectomy: (1) no HT use with or without a uterus, (2) HT use and no uterus (proxy for estrogen only), and (3) HT use and uterus (proxy for estrogen and progestin use). Standardization of the rates by taking a weighted average of the rates for each covariate configuration: the same weights were used for nonusers, estrogen and progestin users, and estrogen only users. Adjustment for age, Race, family history of breast cancer, examination year, time between mammography examinations, and mammography registry.
Patel, 2003^78^ Country: USA Design: Case control study Evidence: IIB Time Period: March 1, 1995-May 31, 1998 Length of followup/months: N/A | Data source: The Cancer Surveillance Program and the Women’s Contraceptive and Reproductive Experiences Study Inclusion criteria: All study participants were English-speaking, U.S.-born white (including Hispanic) and black female residents of Los Angeles County between 35 and 64 years old without prior diagnosis of BCIS or invasive breast carcinoma. All had a working residential telephone at reference date. Control subjects were randomly selected (random-digit dialing) from a group of Los Angeles County control subjects participating in the Women’s Contraceptive and Reproductive Experiences (CARE) Study-multicenter, population-based, case–control study of invasive breast carcinoma among white and black women that began in mid-1994. Response rates were 80% for white patients and 75% for black patients. Response rate in Los Angeles County control subjects was 71% for blacks and 76% for whites Exclusion: Not receiving a mammogram within the 2 years before the study. Inclusion Age: 35–64 Mean age: 51.6 Sample size: 1,183 | Definition: DCIS or LCIS (the results for DCIS only did not differ) diagnosed with histologically confirmed cancer between March 1, 1995 and May 31, 1998, as identified by the University of Southern California Cancer Surveillance Program using ICD-O morphologic codes: 8500–8504, 8522, 8543, and 8573 for DCIS, 8520 for LCIS Masking of outcome assessment: Not reported Control for bias: Adjustment for age, race, education (< high school graduate, some college, >college graduate), income (<$15,000, $15,000–$35,000, >$35,000–$70,000, >$70,000), family history of breast carcinoma in mother, sisters, or daughters (yes, no, not known), age at menarche (younger than 12 years, ages 12–13 years, older than 13 years), smoking status (never, current, former), body mass index (BMI [kg/m2]; <25.0, 25.0 to <30.0, >30.0), oral contraceptive use (never, <2 years, 2–5 years, >5 years), number of pregnancies with gestational length greater than 26 weeks (none, 1–2, >2), menopausal status (premenopausal, perimenopausal, postmenopausal, unknown), age at menopause (younger than 50 years, ages 50–54 years, 55 years or older, unknown), postmenopausal hormone replacement therapy use (HRT) (never, ever estrogen use [unopposed or opposed], ever other hormone use), and recency of HRT use (never, <5 years from reference date, >5 years from reference date). Frequency matching within the strata of geographic site, race, and 5-year age group.
Wohlfahrt, 2004^79^ Country: Denmark Design: Prospective cohort study Evidence: IIA Time Period: January 1, 1983-December 31, 1998 Length of followup/months: 22.5 million person years | Data source: The Civil Registration System to establish a national parity database including all women born between April 1, 1935 and March 31, 1978. The Danish Breast Cancer Cooperative Group (DBCG) registry Inclusion criteria: All Danish women born between 1935 and 1978 Exclusion: Not reported Inclusion Age: >47 Mean age: Sample size: 1,500,000 | Definition: DCIS confirmed in the National Cancer Registry Masking of outcome assessment: Not reported Control for bias: Adjustment for age (quadratic splines with knots: 30, 35, 40, 45, 50, 55, 60), calendar year (1983–1987, 1988–1992, 1993–1998), age at first birth (nulliparous, 12–19, 20–24, 25–29, 30–34, >34) and parity (nulliparous, 1, 2, 3, 4+).
Anderson, 2004^35^ Country: USA Design: Prospective cohort study Evidence: IIA Time Period: 1973–2000 Length of followup/months: N/A | Data source: The Surveillance, Epidemiology, and End Results program of the National Cancer Institute Inclusion criteria: All women with DCIS identified in 9 original population-based registries: Connecticut, Hawaii, Iowa, Utah, and New Mexico and metropolitan areas of San Francisco, Detroit, Atlanta, and Seattle-Puget Sound. Exclusion: Not reported Inclusion Age: All ages; Mean age: 59 Sample size: 430,454 | Definition: DCIS identified in SEER database Masking of outcome assessment: Not reported Control for bias: Standardization to the 2000 U.S. standard to calculated age-adjusted incidence rate ratio
Anderson, 2004^35^ Country: USA Design: Prospective cohort study Evidence: IIA Time Period: 1973–2000 Length of followup/months: N/A | Data source: The Surveillance, Epidemiology, and End Results program of the National Cancer Institute Inclusion criteria: All women with DCIS identified in 9 original population-based registries: Connecticut, Hawaii, Iowa, Utah, and New Mexico and metropolitan areas of San Francisco, Detroit, Atlanta, and Seattle-Puget Sound. Exclusion: Not reported Inclusion Age: All ages Sample size: 430,465 | Definition: DCIS identified in SEER database Masking of outcome assessment: Not reported Control for bias: Standardization to the 2000 U.S. standard to calculated age-adjusted incidence rate ratio
Kerlikowske, 2005^47^ Country: USA Design: Retrospective cohort Evidence: II-2C Time Period: January 1986- December 2001 Length of followup/months: 12 | Data source: California Cancer Registry Inclusion criteria: Retrospective review of all women 40 years and older who were asymptomatic and underwent a bilateral mammography examination directly recorded by the radiologist as having been performed for screening in San Francisco County between January 1986 and December 2001. Exclusion: Screening examinations that occurred after December 2001 were excluded; prior breast cancer diagnosis, breast augmentation, reduction or reconstruction, or history of mastectomy Inclusion Age: >40; Mean age: Not specified Sample size: 65,628 | Definition: Report of medical diagnosis of DCIS Masking of outcome assessment: Not reported Control for bias: Race
Zeleniuch-Jacquotte, 2005^80^ Country: USA Design: Nested (New York University Women’s Health Study) Case control study Evidence: II-3 Time Period: 1985–1991 Length of followup/months: 84 | Data source: New York University Women’s Health Study Inclusion criteria: 14,275 healthy women ages 34–65, participants of the NYU Women’s Health Study in breast cancer screening center in New York City between 1985 and 1991. Controls were selected at random from the appropriate risk sets in ratio 2:1. The risk set for a case consisted of all women who were postmenopausal at enrollment, were alive and free of cancer at the time of diagnosis of the case and matched the case on age at enrollment (±6 months), date of enrollment (±3 months) and number (1, 2, 3+) and dates (±3 months) of subsequent blood donations, if any. Exclusion: Pregnancy, hormone medication use in the 6 months preceding the study Inclusion Age: 34–65; Mean age: Median age at enrollment was 58 years Sample size: 203 | Definition: Self reported DCIS with a record linkage to the U.S. National Death Index and state cancer registries in New York, New Jersey, and Florida Masking of outcome assessment: Laboratory personnel who measured hormones were blinded as to case/control status Control for bias: Adjusted for age
Reeves, 2006^81^ Country: UK, Australia, New Zealand Design: Evidence: II-2A Time Period: 1996–2001 Length of followup/months: 32.4 | Data source: UK National Health Service (NHS) Central Registers Inclusion criteria: All UK women ages 50–64 who are registered with a general practitioner and who responded to invitations Exclusion: Invasive cancer other than non-melanoma skin cancer (ICD10 C44) before recruitment Inclusion Age: 50–64; Mean age: 59 Sample size: 1,031,224 | Definition: ICD10-0 code 8500/2 Masking of outcome assessment: Not reported Control for bias: Relative risk stratified by age at entry, and adjusted for region, age at birth of first child, parity, time since menopause, deprivation index, BMI, and family history of breast cancer
Chen, 2006^82^ Country: USA Design: Cross-sectional Evidence: II-2B Time Period: January 1, 1988-December 31, 2002 Length of followup/months: 48 | Data source: the U.S. is the Surveillance, Epidemiology, and End Results (SEER) registry of the National Cancer Institute Inclusion criteria: Women with DCIS and Paget disease of the breast diagnosed from January 1, 1988-December 31, 2002, and identified in 9 population-based registries in the U.S. is the Surveillance, Epidemiology, and End Results (SEER) registry of the National Cancer Institute data base (November 2004 submission): 618 patients. 21,426 women with standard DCIS diagnosed at the same time period were enrolled as controls Exclusion: Prior history of any type of cancer, positive lymph nodes Inclusion Age: NS; Mean age: 63.8 Sample size: 21,426 | Definition: DCIS and Paget disease coded with the International Classification of Disease for Oncology 2nd edition (ICD-O-2): code 8500.w (ductal carcinoma in situ) and code 8543 (Paget disease with Intraductal carcinoma). Masking of outcome assessment: Not reported Control for bias: Age adjustment according to the 2000 U.S. standard population (19 age groups; Census P25–1130)
Vamre, 2006^83^ Country: Norway Design: Cross-sectional Evidence: IIB Time Period: N/S Length of followup/months: N/A | Data source: WHO Collaborative study of Neoplasia and Steroid Contraceptives: multinational study Inclusion criteria: Retrospective review of 10 2,476 randomly selected histological materials of non-neoplastic surrounding breast tissue from women with breast cancer, participants in the WHO study who were free from invasive carcinoma but slides contained recognizable non-neoplastic epithelial tissue. Reproductive age after the introduction of steroid contraceptives Exclusion: Missing information about oral contraceptive use Inclusion Age: >55; Mean age: NS Sample size: 1,503 | Definition: DCIS Masking of outcome assessment: The slide readings were performed without any knowledge of patients’ age, or other clinical data Control for bias: Adjustment for age at diagnosis (by 5-year age groups) and country of residence
Cuzick, 2007^84^ Country: UK, Australia, New Zealand Design: randomized controlled clinical trial Evidence: I Time Period: 1992–2006 Length of followup/months: 96 | Data source: IBIS (International Breast Cancer Intervention Study) center Inclusion criteria: Women ages 35–70 years with risk factors for breast cancer indicating at least a twofold relative risk if they were 45–70 years of age, a fourfold relative risk if they were 40–44 years of age, or a 10-fold relative risk if they were 35–39 years of age. Women were eligible from age 45 years if they had 1) a mother or sister diagnosed with breast cancer before the age of 50 years, 2) two first-or second-degree relatives with breast cancer at any age, or 3) a first first-degree relative with breast cancer at any age, and either were nulliparous or had a previous hyperplastic benign lesion. Women were eligible from the age of 40 years if they had 1) atypical ductal or lobular hyperplasia, 2) a first first- degree relative with bilateral breast cancer at any age, or 3) two first- or second-degree relatives with breast cancer, one of whom was diagnosed before age 50 years. Women were eligible from the age of 35 years if they had either 1) lobular carcinoma in situ or 2) two first first-degree relatives with breast cancer, both diagnosed before the age of 50 years. Any women with an estimated 10-year risk of 5% or more were also eligible as risk equivalent after approval by the study chairman. Exclusion: Any previous invasive cancer (excluding nonmelanoma skin cancer), previous deep-vein thrombosis or pulmonary embolism, current users of anticoagulants, or planning to become pregnant Inclusion Age: 35–70; Mean age: 50.7 Sample size: 7,145 | Definition: DCIS Masking of outcome assessment: Double blind Control for bias: Intention to treat, after exclusion of the 13 women found to have breast cancer at baseline The mean age was 50.8 years (SD 6.9); 54.7% of the women were between the ages of 45 and 54; 49% were postmenopausal and 41% had previously used hormone-replacement therapy.
Powles, 2007^85^ Country: UK Design: RCT Evidence: I Time Period: October 1, 1986-April 30, 1996 Length of followup/months: 158 | Data source: Royal Marsden randomized, double-blinded tamoxifen breast cancer prevention trial Inclusion criteria: Healthy women between 30 and 70 years old, with no clinical or screening evidence of breast cancer and with an increased risk of breast cancer because of their family history of breast cancer with at least one first-degree relative who was younger than 50 years when diagnosed with breast cancer or one first-degree relative with bilateral breast cancer, or one first degree relative with breast cancer who was diagnosed at any age plus at least one other affected first- or second-degree relative with breast cancer. Women with a history of a benign breast biopsy who had a first-degree relative with breast cancer were also eligible. Exclusion: History of any cancer, deep-vein thrombosis, or pulmonary embolism; risk of pregnancy; using oral contraceptives but not hormone replacement therapy. Inclusion Age: NS; Mean age: 7 (31–70) Sample size: 2,471 | Definition: DCIS Masking of outcome assessment: Participants, clinicians, and data-processing staff Control for bias: Randomized placebo controlled double blind trial with intention to treat analysis, no differences at baseline patient characteristics
Nichols, 2007^86^ Country: USA Design: Case control study Evidence: IIB Time Period: February 1997- May 2001 Length of followup/months: N/A | Data source: The Collaborative Breast Cancer Study in Wisconsin, Massachusetts, and New Hampshire Inclusion criteria: Women 20–74 years old residing in Wisconsin, Massachusetts (excluding metropolitan Boston), and New Hampshire with a new diagnosis of breast carcinoma in situ (ICD-O version 2 C50.0–C50.9) identified in state’s cancer registry from 1997–2001, with listed telephone numbers, driver’s licenses verified by self-report (if <65 years of age), and known dates of diagnosis. 1,694 cases including 1,471 DCIS were eligible. Community controls without personal history of breast cancer, with a listed telephone number, if under 65 years of age, and self- reported driver’s license were randomly selected during 1997–2001 in each state using two sampling frames: those under 65 years of age were selected from lists of licensed drivers, and those 65–74 years of age were selected from a roster of Medicare beneficiaries compiled by the Centers for Medicare & Medicaid Services (8,041 controls) Exclusion: Not having residential phone number Inclusion Age: >20; Mean age: 55.3 years (range, 24–74) Sample size: 9,512 | Definition: DCIS identified by ICD codes as ductal/nonlobular (8500, 8501, 8503, 8504, 8010, and 8140 Masking of outcome assessment: Not reported Control for bias: Stratified by age of cases random selection of controls. Adjustment for age (<40,40–44, 45–49, 50–54, 55–59, 60–64, 65–69, and >70), state (Massachusetts, New Hampshire, Wisconsin), age at menarche (<12, 12, 13, z14, unknown), age at first birth (<20, 20–24, 25–29, >30, unknown), parity (≤1, 2, ≥3, unknown), menopausal status (premenopausal, postmenopausal, unknown), age at menopause (<45, 45–49, 50–54, >55, unknown), postmenopausal hormone use (never, former, current), family history of breast cancer (yes, no, unknown), education (less than high school diploma, high school diploma, some college, college diploma, unknown), smoking status (never, former, current), weight at age 18 (continuous), height (continuous), weight change since age 18 (weight loss, weight gain of 0–15, 16–30, 31–50, >50 lb, unknown), personal history of benign breast disease (yes, no, unknown), and number of mammograms within 5 years before the reference date (none, less than five, five or more, unknown).
MacKenzie, 2007^58^ Country: USA Design: Prospective cohort study Evidence: IIA Time Period: January 1994- December 2001 in VT; June 1996-July 2000 in NH Length of followup/months: 49.2 | Data source: The New Hampshire Mammography Network (NHMN) and the Vermont Breast Cancer Surveillance System (VBCSS) Inclusion criteria: Women at least 40 years of age and had screening mammogram between January 1994 and December 2001 in VT and between June 1996 and July 2000 in NH having at least 60 days of followup in the registry Exclusion: Personal history of breast cancer, breast implants, or breast reduction surgery Inclusion Age: 40–98; Mean age: 52 Sample size: 154,936 | Definition: DCIS identified in registry with SNOMED codes or TNM codes Masking of outcome assessment: Not reported Control for bias: Adjustment for age, parity, BMI, and family history in premenopausal women; adjustment for age, parity, BMI, family history, and HRT in postmenopausal women
Stacey, 2008^87^ Country: Multinational Design: Case-control study Evidence: IIB Time Period: 1993–1996 Length of followup/months: N/A | Data source: Iceland, Sweden, Holland, Spain and the United States Inclusion criteria: Icelandic Cancer Registry (males and females) the Oncology Department of Zaragoza Hospital between March 2006 and August 2007 Swedish Familial and Consecutive patient series in the Karolinska University Hospital, Stockholm. The regional cancer registry held by the Comprehensive Cancer Centre East in Nijmegen, the Netherlands U.S. Multiethnic Cohort: predominantly of African Americans, Native Hawaiians, Japanese Americans, Latinos, and European Americans who entered the study in 1993 and 1996. Incident cancers in the MEC are identified by cohort linkage to population-based cancer Surveillance, Epidemiology and End Results (SEER) registries the Departments of Surgery and Radiotherapy, University College Hospital, Ibadan, Nigeria Exclusion: Not reported Inclusion Age: All ages Sample size: 29,956 | Definition: DCIS Masking of outcome assessment: Not reported Control for bias: Adjustment for common variants on chromosome 5p12 confer susceptibility to estrogen receptor- positive breast cancer
Gill, 2006^51^ Country: USA Design of the Study: Nested Case-control study Evidence: IIB Time Period: 1993–2000 Length of followup/months: N/A | Data source: Hawaii component of the Multiethnic Cohort Inclusion criteria: All female members of multiethnic cohort diagnosed with primary breast cancer between cohort entry and December 2000 were identified as potential cases (n = 1,587). A similar number of randomly selected control subjects (n = 1,584) who were not known to have breast cancer were frequency matched to the distribution of ethnicity and 5-year age groups of the cases. Of the 1,396 cases eligible to participate, 52.6% responded to the mailings and gave full consent. Of the 1,500 eligible controls, 48.7% responded to the mailings and gave full consent. After removing women who did not have suitable mammograms, the final sample consisted of 607 breast cancer cases and 667 control subjects. Exclusion: Cases and controls with a previous diagnosis of breast cancer, a history of breast augmentation or reduction, and no mammogram. Inclusion Age: All ages; Mean age: 62.9–63.5 Sample size: 1,268 | Definition: DCIS recorded in the state-wide Hawaii Tumor Registry, a member of the National Cancer Institute's Surveillance, Epidemiology and End Results program. Masking of outcome assessment: Not reported Control for bias: Adjustment for the following covariates that are known to be associated with breast cancer and mammographic density: mean age of all mammograms (continuous), ethnicity, BMI (<22.5, 22.5 to <25, 25 to <30, or ≥30 kg/m2), parity (0–1, 2–3, or ≥4), age at menarche (<13, 13–14, or ≥15 years), age at first live birth (<21, 21–30, >30 years, or no children), menopausal status (pre- or postmenopausal), family history of breast cancer (breast cancer in a first-degree relative or no history), and HRT use (never, estrogen only, or estrogen + progestin).
Granström, 2008^88^ Country: Sweden Design of the Study: Prospective cohort study Evidence: IIA Time Period: 1993–2004 Length of followup/months: 11 years | Data source: Second Generation Swedish Family Register renamed to Multigeneration Register linked to the Swedish Cancer Registry (1958–2004) to make the Family-Cancer Database (MigMed2). Inclusion criteria: Swedish-born as well as immigrant women born between years 1932 and 1953, that is, those whose minimal age at the beginning of the followup ranged from 40 to 61 years Exclusion: Incompleteness of cancer registration was 5% in the 1970s and close to 0% in 2004. The percentage of cytologically or histologically unverified cases has been close to 0% Inclusion Age: 40–61; Mean age: N/R Sample size: 1,028,455 | Definition: DCIS identified in registry with SNOMED codes or ICD codes Masking of outcome assessment: Not reported Control for bias: Adjustment for age at diagnosis (5-year bands), family history of invasive breast cancer (mother, sister, no history), parity (0, 1, 2, 3+), age at first child birth (13–20, 21–24, 25–29, 30+ years), socioeconomic status (manual worker, blue collar, professional, other) and residential area (big city, south, north)

Table F3 Age adjusted cumulative incidence of DCIS per 100,000 U.S. female population (results from individual studies conducted in the United States are sorted by the year of the events)

Study | DCIS | Cumulative Incidence
Zheng, 1997^17^ Year of the study: 1976–92 Data source: Connecticut Tumor Registry | Method to diagnose DCIS: Mammography Inclusion age: ≥30 years DCIS cases: 96 Year of events: 1973–75 | Age-adjusted incidence rates standardized to 1970 per 100,000 female population: 1.87
Zheng, 1997^17^ Year of the study: 1976–92 Data source: Connecticut Tumor Registry | Method to diagnose DCIS: Mammography Inclusion age: ≥30 years DCIS cases: 97 Year of events: 1976–78 | Age-adjusted incidence rates standardized to 1970 per 100,000 female population: 1.84
Zheng, 1997^17^ Year of the study: 1976–92 Data source: Connecticut Tumor Registry | Method to diagnose DCIS: Mammography Inclusion age: ≥30 years DCIS cases: 126 Year of events: 1979–81 | Age-adjusted incidence rates standardized to 1970 per 100,000 female population: 2.37
Kumar, 2005^43^ Year of the study: 1980–2002 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: N/S Inclusion age: N/S years DCIS cases: 4 Year of events: 1980 | Annual age-adjusted incidence rates per 100,000 (2000 U.S. female population): 4
Li, 2005^44^ Year of the study: 1980–2001 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: Individual patient records Inclusion age: ≥30 years DCIS cases: 4 Year of events: 1980 | Cumulative incidence per 100,000 women for 1 year age- adjusted to the 2000 U.S. population: 4
Sumner, 2007^56^ Year of the study: 1981–2001 Data source: Florida Cancer Data System | Method to diagnose DCIS: Mammography Inclusion age: 18–103 years DCIS cases: 23,810 Year of events: 1981 | Age-adjusted Incidence rates per 100,000 standardized to the U.S. population: 2.4
Li, 2005^44^ Year of the study: 1980–2001 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: Individual patient records Inclusion age: ≥30 years DCIS cases: 4 Year of events: 1981 | Cumulative incidence per 100,000 women for 1 year age- adjusted to the 2000 U.S. population: 4
Zheng, 1997^17^ Year of the study: 1976–92 Data source: Connecticut Tumor Registry | Method to diagnose DCIS: Mammography Inclusion age: ≥30 years DCIS cases: 176 Year of events: 1982–84 | Age-adjusted incidence rates standardized to the 1970 per 100,000 female population: 3.19
Li, 2005^44^ Year of the study: 1980–2001 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: Individual patient records Inclusion age: ≥30 years DCIS cases: 5 Year of events: 1982 | Cumulative incidence per 100,000 women for 1 year age- adjusted to the 2000 U.S. population: 5
Kumar, 2005^43^ Year of the study: 1980–2002 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: N/S Inclusion age: N/S years DCIS cases: 5 Year of events: 1983 | Annual age-adjusted incidence rates per 100,000 (2000 U.S. female population): 5
Li, 2005^44^ Year of the study: 1980–2001 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: Individual patient records Inclusion age: ≥30 years DCIS cases: 5 Year of events: 1983 | Cumulative incidence per 100,000 women for 1 year age- adjusted to the 2000 U.S. population: 5
Kumar, 2005^43^ Year of the study: 1980–2002 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: N/S Inclusion age: N/S years DCIS cases: 7.8 Year of events: 1984 | Annual age-adjusted incidence rates per 100,000 (2000 U.S. female population): 7.8
Li, 2005^44^ Year of the study: 1980–2001 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: Individual patient records Inclusion age: ≥30 years DCIS cases: 8 Year of events: 1984 | Cumulative incidence per 100,000 women for 1 year age- adjusted to the 2000 U.S. population: 8
Zheng, 1997^17^ Year of the study: 1976–92 Data source: Connecticut Tumor Registry | Method to diagnose DCIS: Mammography Inclusion age: ≥30 years DCIS cases: 483 Year of events: 1985–87 | Age-adjusted incidence rates standardized to 1970 per 100,000 female population: 8.5
Li, 2005^44^ Year of the study: 1980–2001 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: Individual patient records Inclusion age: ≥30 years DCIS cases: 11 Year of events: 1985 | Cumulative incidence per 100,000 women for 1 year age- adjusted to the 2000 U.S. population: 11
| Method to diagnose DCIS: Individual patient records Inclusion age:≥30 years DCIS cases: 13.5 Year of events: 1986 | Cumulative incidence per 100,000 women for 1 year age- adjusted to the 2000 U.S. population: 13.5
Coburn, 2004^34^ Year of the study: 1987–2001 Data source: Rhode Island Cancer Registry | Method to diagnose DCIS: Mammogram Inclusion age: All ages DCIS cases: 12.5 Year of events: 1987–1989 | Cumulative incidence rate per 100,000 over 2 years: 12.5
Coburn, 2004^34^ Year of the study: 1987–2001 Data source: Rhode Island Cancer Registry | Method to diagnose DCIS: Mammogram Inclusion age: All ages DCIS cases: 10 Year of events: 1987 | Cumulative incidence rate per 100,000 over 1 year: 10
Li, 2005^44^ Year of the study: 1980–2001 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: Individual patient records Inclusion age: ≥30 years DCIS cases: 18 Year of events: 1987 | Cumulative incidence per 100,000 women for 1 year age- adjusted to the 2000 U.S. population: 18
Zheng, 1997^17^ Year of the study: 1976–92 Data source: Connecticut Tumor Registry | Method to diagnose DCIS: Mammography Inclusion age: ≥30 years DCIS cases: 698 Year of events: 1988–90 | Age-adjusted incidence rates standardized to the 1970 per 100,000 female population: 11.84
Coburn, 2004^34^ Year of the study: 1987–2001 Data source: Rhode Island Cancer Registry | Method to diagnose DCIS: Mammogram Inclusion age: All ages DCIS cases: 13 Year of events: 1988 | Cumulative incidence rate per 100,000 over 1 year: 13
Li, 2005^44^ Year of the study: 1980–2001 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: Individual patient records Inclusion age: ≥30 years DCIS cases: 19 Year of events: 1988 | Cumulative incidence per 100,000 women for 1 year age- adjusted to the 2000 U.S. population: 19
Coburn, 2004^34^ Year of the study: 1987–2001 Data source: Rhode Island Cancer Registry | Method to diagnose DCIS: Mammogram Inclusion age: All ages DCIS cases: 16 Year of events: 1989 | Cumulative incidence rate per 100,000 over 1 year: 16
Li, 2005^44^ Year of the study: 1980–2001 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: Individual patient records Inclusion age: ≥30 years DCIS cases: 18 Year of events: 1989 | Cumulative incidence per 100,000 women for 1 year age- adjusted to the 2000 U.S. population: 18
Coburn, 2004^34^ Year of the study: 1987–2001 Data source: Rhode Island Cancer Registry | Method to diagnose DCIS: Mammogram Inclusion age: All ages DCIS cases: 15 Year of events: 1990 | Cumulative incidence rate per 100,000 over 1 year: 15
Li, 2005^44^ Year of the study: 1980–2001 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: Individual patient records Inclusion age: ≥30 years DCIS cases: 22 Year of events: 1990 | Cumulative incidence per 100,000 women for 1 year age- adjusted to the 2000 U.S. population: 22
Zheng, 1997^17^ Year of the study: 1976–92 Data source: Connecticut Tumor Registry | Method to diagnose DCIS: Mammography Inclusion age: ≥30 years DCIS cases: 567 Year of events: 1991–92 | Age-adjusted incidence rates standardized to 1970 per 100,000 female population: 14.06
Coburn, 2004^34^ Year of the study: 1987–2001 Data source: Rhode Island Cancer Registry | Method to diagnose DCIS: Mammogram Inclusion age: All ages DCIS cases: 20 Year of events: 1991 | Cumulative incidence rate per 100,000 over 1 year: 20
Li, 2005^44^ Year of the study: 1980–2001 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: Individual patient records Inclusion age: ≥30 years DCIS cases: 22.5 Year of events: 1991 | Cumulative incidence per 100,000 women for 1 year age- adjusted to the 2000 U.S. population: 22.5
Coburn, 2004^34^ Year of the study: 1987–2001 Data source: Rhode Island Cancer Registry | Method to diagnose DCIS: Mammogram Inclusion age: All ages DCIS cases: 17 Year of events: 1992 | Cumulative incidence rate per 100,000 over 1 year: 17
Kumar, 2005^43^ Year of the study: 1980–2002 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: N/S Inclusion age: N/S years DCIS cases: 23.8 Year of events: 1992 | Annual age-adjusted incidence rates per 100,000 (2000 U.S. female population): 23.8
Li, 2005^44^ Year of the study: 1980–2001 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: Individual patient records Inclusion age: ≥30 years DCIS cases: 24 Year of events: 1992 | Cumulative incidence per 100,000 women for 1 year age- adjusted to the 2000 U.S. population: 24
Coburn, 2004^34^ Year of the study: 1987–2001 Data source: Rhode Island Cancer Registry | Method to diagnose DCIS: Mammogram Inclusion age: All ages DCIS cases: 17 Year of events: 1993 | Cumulative incidence rate per 100,000 over 1 year: 17
Li, 2005^44^ Year of the study: 1980–2001 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: Individual patient records Inclusion age: ≥30 years DCIS cases: 23.5 Year of events: 1993 | Cumulative incidence per 100,000 women for 1 year age- adjusted to the 2000 U.S. population: 23.5
Coburn, 2004^34^ Year of the study: 1987–2001 Data source: Rhode Island Cancer Registry | Method to diagnose DCIS: Mammogram Inclusion age: All ages DCIS cases: 18 Year of events: 1994 | Cumulative incidence rate per 100,000 over 1 year: 18
Li, 2005^44^ Year of the study: 1980–2001 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: Individual patient records Inclusion age: ≥30 years DCIS cases: 25 Year of events: 1994 | Cumulative incidence per 100,000 women for 1 year age- adjusted to the 2000 U.S. population: 25
Coburn, 2004^34^ Year of the study: 1987–2001 Data source: Rhode Island Cancer Registry | Method to diagnose DCIS: Mammogram Inclusion age: All ages DCIS cases: 18 Year of events: 1995 | Cumulative incidence rate per 100,000 over 1 year: 18
Kumar, 2005^43^ Year of the study: 1980–2002 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: N/S Inclusion age: N/S years DCIS cases: 28.8 Year of events: 1995 | Annual age-adjusted incidence rates per 100,000 (2000 U.S. female population): 28.8
Li, 2005^44^ Year of the study: 1980–2001 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: Individual patient records Inclusion age: ≥30 years DCIS cases: 28.5 Year of events: 1995 | Cumulative incidence per 100,000 women for 1 year age- adjusted to the 2000 U.S. population: 28.5
Coburn, 2004^34^ Year of the study: 1987–2001 Data source: Rhode Island Cancer Registry | Method to diagnose DCIS: Mammogram Inclusion age: All ages DCIS cases: 25 Year of events: 1996 | Cumulative incidence rate per 100,000 over 1 year: 25
Li, 2005^44^ Year of the study: 1980–2001 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: Individual patient records Inclusion age: ≥30 years DCIS cases: 29.5 Year of events: 1996 | Cumulative incidence per 100,000 women for 1 year age- adjusted to the 2000 U.S. population: 29.5
Coburn, 2004^34^ Year of the study: 1987–2001 Data source: Rhode Island Cancer Registry | Method to diagnose DCIS: Mammogram Inclusion age: All ages DCIS cases: 23 Year of events: 1997 | Cumulative incidence rate per 100,000 over 1 year: 23
Li, 2005^44^ Year of the study: 1980–2001 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: Individual patient records Inclusion age: ≥30 years DCIS cases: 33 Year of events: 1997 | Cumulative incidence per 100,000 women for 1 year age- adjusted to the 2000 U.S. population: 33
Coburn, 2004^34^ Year of the study: 1987–2001 Data source: Rhode Island Cancer Registry | Method to diagnose DCIS: Mammogram Inclusion age: All ages DCIS cases: 27 Year of events: 1998 | Cumulative incidence rate per 100,000 over 1 year: 27
Kumar, 2005^43^ Year of the study: 1980–2002 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: N/S Inclusion age: N/S years DCIS cases: 38 Year of events: 1998 | Annual age-adjusted incidence rates per 100,000 (2000 U.S. female population): 38
Li, 2005^44^ Year of the study: 1980–2001 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: Individual patient records Inclusion age: ≥30 years DCIS cases: 38 Year of events: 1998 | Cumulative incidence per 100,000 women for 1 year age- adjusted to the 2000 U.S. population: 38
Coburn, 2004^34^ Year of the study: 1987–2001 Data source: Rhode Island Cancer Registry | Method to diagnose DCIS: Mammogram Inclusion age: All ages DCIS cases: 33.5 Year of events: 1999–2001 | Cumulative incidence rate per 100,000 over 2 years: 33.5
Coburn, 2004^34^ Year of the study: 1987–2001 Data source: Rhode Island Cancer Registry | Method to diagnose DCIS: Mammogram Inclusion age: All ages DCIS cases: 35 Year of events: 1999 | Cumulative incidence rate per 100,000 over 1 year: 35
Li, 2005^44^ Year of the study: 1980–2001 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: Individual patient records Inclusion age: ≥30 years DCIS cases: 37 Year of events: 1999 | Cumulative incidence per 100,000 women for 1 year age- adjusted to the 2000 U.S. population: 37
Coburn, 2004^34^ Year of the study: 1987–2001 Data source: Rhode Island Cancer Registry | Method to diagnose DCIS: Mammogram Inclusion age: All ages DCIS cases: 36 Year of events: 2000 | Cumulative incidence rate per 100,000 over 1 year: 36
Li, 2005^44^ Year of the study: 1980–2001 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: Individual patient records Inclusion age: ≥30 years DCIS cases: 37.5 Year of events: 2000 | Cumulative incidence per 100,000 women for 1 year age- adjusted to the 2000 U.S. population: 37.5
Sumner, 2007^56^ Year of the study: 1981–2001 Data source: Florida Cancer Data System | Method to diagnose DCIS: Mammography Inclusion age: 18–103 years DCIS cases: 23,810 Year of events: 2001 | Age-adjusted Incidence rates per 100,000 standardized to the U.S. population: 27.7
Coburn, 2004^34^ Year of the study: 1987–2001 Data source: Rhode Island Cancer Registry | Method to diagnose DCIS: Mammogram Inclusion age: All ages years DCIS cases: 33 Year of events: 2001 | Cumulative incidence rate per 100,000 over 1 year: 33
Kumar, 2005^43^ Year of the study: 1980–2002 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: N/S Inclusion age: N/S years DCIS cases: 37.8 Year of events: 2001 | Annual age-adjusted incidence rates per 100,000 (2000 U.S. female population): 37.8
Li, 2005^44^ Year of the study: 1980–2001 Data source: 9 SEER registries in Connecticut, Hawaii, Iowa, New Mexico, and Utah and in the metropolitan areas of Atlanta, Detroit, San Francisco-Oakland, and Seattle-Puget Sound | Method to diagnose DCIS: Individual patient records Inclusion age: ≥30 years DCIS cases: 37.5 Year of events: 2001 | Cumulative incidence per 100,000 women for 1 year age- adjusted to the 2000 U.S. population: 37.5
SEER registry data with the same time periods as Li, 2005 44
Baxter, 2004^33^ Year of the study: 1992–1999 Data source: SEER Registry (11 population-based cancer registries and 3 supplemental registries that were added to SEER in January 1992) | Method to diagnose DCIS: N/S Inclusion age: >18 years DCIS cases: 18 Year of events: 1992 | Age-adjusted annual incidence per 100,000 women (2000 U.S. Census): 18
Baxter, 2004^33^ Year of the study: 1992–1999 Data source: SEER Registry (11 population-based cancer registries and 3 supplemental registries that were added to SEER in January 1992) | Method to diagnose DCIS: N/S Inclusion age: >18 years DCIS cases: 17.5 Year of events: 1993 | Age-adjusted annual incidence per 100,000 women (2000 U.S. Census): 17.5
Baxter, 2004^33^ Year of the study: 1992–1999 Data source: SEER Registry (11 population-based cancer registries and 3 supplemental registries that were added to SEER in January 1992) | Method to diagnose DCIS: N/S Inclusion age: >18 years DCIS cases: 19 Year of events: 1994 | Age-adjusted annual incidence per 100,000 women (2000 U.S. Census): 19
Baxter, 2004^33^ Year of the study: 1992–1999 Data source: SEER Registry (11 population-based cancer registries and 3 supplemental registries that were added to SEER in January 1992) | Method to diagnose DCIS: N/S Inclusion age: >18 years DCIS cases: 21.5 Year of events: 1995 | Age-adjusted annual incidence per 100,000 women (2000 U.S. Census): 21.5
Baxter, 2004^33^ Year of the study: 1992–1999 Data source: SEER Registry (11 population-based cancer registries and 3 supplemental registries that were added to SEER in January 1992) | Method to diagnose DCIS: N/S Inclusion age: >18 years DCIS cases: 22 Year of events: 1996 | Age-adjusted annual incidence per 100,000 women (2000 U.S. Census): 22
Baxter, 2004^33^ Year of the study: 1992–1999 Data source: SEER Registry (11 population-based cancer registries and 3 supplemental registries that were added to SEER in January 1992) | Method to diagnose DCIS: N/S Inclusion age: >18 years DCIS cases: 25 Year of events: 1997 | Age-adjusted annual incidence per 100,000 women (2000 U.S. Census): 25
Baxter, 2004^33^ Year of the study: 1992–1999 Data source: SEER Registry (11 population-based cancer registries and 3 supplemental registries that were added to SEER in January 1992) | Method to diagnose DCIS: N/S Inclusion age: >18 years DCIS cases: 27.5 Year of events: 1998 | Age-adjusted annual incidence per 100,000 women (2000 U.S. Census): 27.5
Baxter, 2004^33^ Year of the study: 1992–1999 Data source: SEER Registry (11 population-based cancer registries and 3 supplemental registries that were added to SEER in January 1992) | Method to diagnose DCIS: N/S Inclusion age: >18 years DCIS cases: 28 Year of events: 1999 | Age-adjusted annual incidence per 100,000 women (2000 U.S. Census): 28

Table F4 Age adjusted cumulative incidence of DCIS per 100,000 female population (results from individual studies conducted in different countries)

Study | DCIS | Cumulative Incidence per 100,000 Females (95% CI)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 | Method to diagnose DCIS: Mammography DCIS cases: 3.5 Year of events: 1989 | Country: Netherlands Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 3.5 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 | DCIS cases: 4 Year of events: 1990 | Country: Netherlands Cumulative incidence: 4 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 | DCIS cases: 6 Year of events: 1991 | Country: Netherlands Cumulative incidence: 6 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 | DCIS cases: 8 Year of events: 1992 | Country: Netherlands Cumulative incidence: 8 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 | DCIS cases: 9 Year of events: 1993 | Country: Netherlands Cumulative incidence: 9 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 | DCIS cases: 9.5 Year of events: 1994 | Country: Netherlands Cumulative incidence: 9.5 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 | DCIS cases: 9.5 Year of events: 1995 | Country: Netherlands Cumulative incidence: 9.5 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 | DCIS cases: 10 Year of events: 1996 | Country: Netherlands Cumulative incidence: 10 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 | DCIS cases: 11 Year of events: 1997 | Country: Netherlands Cumulative incidence: 11 (N/R; N/R)
Kricker, 2004^38^ Year of the study: 1995–2000 Data source: New South Wales Central Cancer Registry | Method to diagnose DCIS: Mammography DCIS cases: 8.6 Year of events: 1995–2000 | Country: Australia Cumulative incidence per 100,000 women age standardized to the World population from 1995–2000: 8.6 (8.2; 9)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud | Method to diagnose DCIS: N/S DCIS cases: 11 Year of events: 1977–1979 | Country: Switzerland Cumulative incidence per 100,000 women age- standardized to the world population from 1977–1979: 1 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud | Method to diagnose DCIS: N/S DCIS cases: 24 Year of events: 1980–1982 | Country: Switzerland Cumulative incidence per 100,000 women age- standardized to the world population from 1980–1982: 2.2 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud | Method to diagnose DCIS: N/S DCIS cases: 20 Year of events: 1983–1985 | Country: Switzerland Cumulative incidence per 100,000 women age- standardized to the world population from 1983–1985: 1.5 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud | Method to diagnose DCIS: N/S DCIS cases: 34 Year of events: 1986–1988 | Country: Switzerland Cumulative incidence per 100,000 women age- standardized to the world population from 1986–1988: 2.9 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud | Method to diagnose DCIS: N/S DCIS cases: 83 Year of events: 1989–1991 | Country: Switzerland Cumulative incidence per 100,000 women age- standardized to the world population from 1989–1991: 6.6 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud | Method to diagnose DCIS: N/S DCIS cases: 92 Year of events: 1992–1994 | Country: Switzerland Cumulative incidence per 100,000 women age- standardized to the world population from 1992–1994: 7.1 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud | Method to diagnose DCIS: N/S DCIS cases: 11 Year of events: 1977–1979 | Country: Switzerland Cumulative incidence per 100,000 women age- standardized to the U.S. 1970 census population from 1977–1979: 1.1 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud | Method to diagnose DCIS: N/S DCIS cases: 24 Year of events: 1980–1982 | Country: Switzerland Cumulative incidence per 100,000 women age- standardized to the U.S. 1970 census population from1980–1982: 2.4 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud | Method to diagnose DCIS: N/S DCIS cases: 20 Year of events: 1983–1985 | Country: Switzerland Cumulative incidence per 100,000 women age- standardized to the U.S. 1970 census population from1983–1985: 1.8 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud | Method to diagnose DCIS: N/S DCIS cases: 34 Year of events: 1986–1988 | Country: Switzerland Cumulative incidence per 100,000 women age- standardized to the U.S. 1970 census population from1986–1988: 3.2 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud | Method to diagnose DCIS: N/S DCIS cases: 83 Year of events: 1989–1991 | Country: Switzerland Cumulative incidence per 100,000 women age- standardized to the U.S. 1970 census population from1989–1991: 7.3 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud | Method to diagnose DCIS: N/S DCIS cases: 92 Year of events: 1992–1994 | Country: Switzerland Cumulative incidence per 100,000 women age- standardized to the U.S. 1970 census population from1992–1994: 7.9 (N/R; N/R)
Barchielli, 1999^26^ Year of the study: 1985–1995 Data source: Tuscany cancer registry | Method to diagnose DCIS: Mammography DCIS cases: 2.1 Year of events: 1985–1987 | Country: Italy Per 100,000 women: 2.1 (N/R; N/R)
Barchielli, 1999^26^ Year of the study: 1985–1995 Data source: Tuscany cancer registry | Method to diagnose DCIS: Mammography DCIS cases: 2.7 Year of events: 1988–1989 | Country: Italy Per 100,000 women: 2.7 (N/R; N/R)
Barchielli, 1999^26^ Year of the study: 1985–1995 Data source: Tuscany cancer registry | Method to diagnose DCIS: Mammography DCIS cases: 3.1 Year of events: 1990–1991 | Country: Italy Per 100,000 women: 3.1 (N/R; N/R)
Barchielli, 1999^26^ Year of the study: 1985–1995 Data source: Tuscany cancer registry | Method to diagnose DCIS: Mammography DCIS cases: 5.6 Year of events: 1992–1993 | Country: Italy Per 100,000 women: 5.6 (N/R; N/R)
Barchielli, 1999^26^ Year of the study: 1985–1995 Data source: Tuscany cancer registry | Method to diagnose DCIS: Mammography DCIS cases: 6 Year of events: 1994–1995 | Country: Italy Per 100,000 women: 6 (N/R; N/R)

Table F5 Cumulative incidence of DCIS per 100,000 female population in age categories (results from individual studies conducted in different countries sorted by country and age category)

Study | DCIS | Age category, Cumulative incidence (95% CI)
Kricker, 2004^38^ Year of the study: 1995–2000 Data source: New South Wales Central Cancer Registry Country: Australia | Method to diagnose DCIS: Mammography DCIS cases: 1.4 Year of events: 1995–2000 | Age category: 20–39 Cumulative incidence per 100,000 women age standardized to the world population from 1995–2000: 1.4 (1.1; 1.7)
Kricker, 2004^38^ Year of the study: 1995–2000 Data source: New South Wales Central Cancer Registry Country: Australia | Method to diagnose DCIS: Mammography DCIS cases: 17.3 Year of events: 1995–2000 | Age category: 40–49 Cumulative incidence per 100,000 women age standardized to the world population from 1995–2000: 17.3 (15.7; 19)
Kricker, 2004^38^ Year of the study: 1995–2000 Data source: New South Wales Central Cancer Registry Country: Australia | Method to diagnose DCIS: Mammography DCIS cases: 31.8 Year of events: 1995–2000 | Age category: 50–59 Cumulative incidence per 100,000 women age standardized to the world population from 1995–2000: 31.8 (29.4; 34.4)
Kricker, 2004^38^ Year of the study: 1995–2000 Data source: New South Wales Central Cancer Registry Country: Australia | Method to diagnose DCIS: Mammography DCIS cases: 32.2 Year of events: 1995–2000 | Age category: 50–69 Cumulative incidence per 100,000 women age standardized to the world population from 1995–2000: 32.2 (30.4; 34.2)
Kricker, 2004^38^ Year of the study: 1995–2000 Data source: New South Wales Central Cancer Registry Country: Australia | Method to diagnose DCIS: Mammography DCIS cases: 32.8 Year of events: 1995–2000 | Age category: 60–69 Cumulative incidence per 100,000 women age standardized to the world population from 1995–2000: 32.8 (29.9; 35.8)
Kricker, 2004^38^ Year of the study: 1995–2000 Data source: New South Wales Central Cancer Registry Country: Australia | Method to diagnose DCIS: Mammography DCIS cases: 24.2 Year of events: 1995–2000 | Age category: 70+ Cumulative incidence per 100,000 women age standardized to the world population from 1995–2000: 24.2 (21.9; 26.7)
Kricker, 2004^38^ Year of the study: 1995–2000 Data source: New South Wales Central Cancer Registry Country: Australia | Method to diagnose DCIS: Mammography DCIS cases: 28.8 Year of events: 1995–2000 | Age category: 70–79 Cumulative incidence per 100,000 women age standardized to the world population from 1995–2000: 28.8 (25.8; 32)
Kricker, 2004^38^ Year of the study: 1995–2000 Data source: New South Wales Central Cancer Registry Country: Australia | Method to diagnose DCIS: Mammography DCIS cases: 10.6 Year of events: 1995–2000 | Age category: 80+ Cumulative incidence per 100,000 women age standardized to the world population from 1995–2000: 10.6 (8.4; 13.3)
Barchielli, 2005^39^ Year of the study: 1988–1999 Data source: Italian cancer registry and screening programmes Country: Italy | Method to diagnose DCIS: Pre- screening DCIS cases: 67 Year of events: 1992–1997 | Age category: 40–79 (Age-adjusted, standard: European population, per 100,000: 10.2 (6.2; 14.2)
Barchielli, 2005^39^ Year of the study: 1988–1999 Data source: Italian cancer registry and screening programmes Country: Italy | Method to diagnose DCIS: Pre- screening DCIS cases: 31 Year of events: 1988–1990 | Age category: 40–79 (Age-adjusted, standard: European population, per 100,000: 9.3 (5.6; 12.9)
Barchielli, 2005^39^ Year of the study: 1988–1999 Data source: Italian cancer registry and screening programmes Country: Italy | Method to diagnose DCIS: Pre- screening DCIS cases: 24 Year of events: 1994–1997 | Age category: 40–79 (Age-adjusted, standard: European population, per 100,000: 10.3 (5.6; 15.1)
Barchielli, 2005^39^ Year of the study: 1988–1999 Data source: Italian cancer registry and screening programmes Country: Italy | Method to diagnose DCIS: Pre- screening DCIS cases: 84 Year of events: 1992–1994 | Age category: 40–79 (Age-adjusted, standard: European population, per 100,000: 8.6 (6.1; 11)
Barchielli, 2005^39^ Year of the study: 1988–1999 Data source: Italian cancer registry and screening programmes Country: Italy | Method to diagnose DCIS: Mammography DCIS cases: 33 Year of events: 1997–1999 | Age category: 40–79 (Age-adjusted, standard: European population, per 100,000: 11.42 (N/R; N/R)
Barchielli, 2005^39^ Year of the study: 1988–1999 Data source: Italian cancer registry and screening programmes Country: Italy | Method to diagnose DCIS: Mammography DCIS cases: 108 Year of events: 1990–1996 | Age category: 40–79 (Age-adjusted, standard: European population, per 100,000: 12.64 (N/R; N/R)
Barchielli, 2005^39^ Year of the study: 1988–1999 Data source: Italian cancer registry and screening programmes Country: Italy | Method to diagnose DCIS: Mammography DCIS cases: 173 Year of events: 1995–1998 | Age category: 40–79 (Age-adjusted, standard: European population, per 100,000: 20.99 (N/R; N/R)
Barchielli, 2005^39^ Year of the study: 1988–1999 Data source: Italian cancer registry and screening programmes Country: Italy | Method to diagnose DCIS: Mammography DCIS cases: 26 Year of events: 1998 | Age category: 40–79 (Age-adjusted, standard: European population, per 100,000: 16.07 (N/R; N/R)
Barchielli, 2005^39^ Year of the study: 1988–1999 Data source: Italian cancer registry and screening programmes Country: Italy | Method to diagnose DCIS: Mammography DCIS cases: 216 Year of events: 1997–1999 | Age category: 40–79 (Age-adjusted, standard: European population, per 100,000: 15.22 (N/R; N/R)
Barchielli, 2005^39^ Year of the study: 1988–1999 Data source: Italian cancer registry and screening programmes Country: Italy | Method to diagnose DCIS: Pre- screening DCIS cases: 93 Year of events: 1992–1995 | Age category: 50–59 (Age-adjusted, standard: European population, per 100,000: 13.9 (10.8; 17.1)
Barchielli, 2005^39^ Year of the study: 1988–1999 Data source: Italian cancer registry and screening programmes Country: Italy | Method to diagnose DCIS: Pre- screening DCIS cases: 68 Year of events: 1988–1991 | Age category: 50–59 (Age-adjusted, standard: European population, per 100,000: 5.1 (3.7; 6.5)
Barchielli, 2005^39^ Year of the study: 1988–1999 Data source: Italian cancer registry and screening programmes Country: Italy | Method to diagnose DCIS: Mammography DCIS cases: 146 Year of events: 1992–1995 | Age category: 50–59 (Age-adjusted, standard: European population, per 100,000: 7.96 (N/R; N/R)
Barchielli, 1999^26^ Year of the study: 1985–1995 Data source: Tuscany cancer registry Country: Italy | Method to diagnose DCIS: Mammography DCIS cases: 4.5 Year of events: 1985–1987 | Age category: 50–69 Per 100,000 women: 4.5 (N/R; N/R)
Barchielli, 1999^26^ Year of the study: 1985–1995 Data source: Tuscany cancer registry Country: Italy | Method to diagnose DCIS: Mammography DCIS cases: 8 Year of events: 1988–1989 | Age category: 50–69 Per 100,000 women: 8 (N/R; N/R)
Barchielli, 1999^26^ Year of the study: 1985–1995 Data source: Tuscany cancer registry Country: Italy | Method to diagnose DCIS: Mammography DCIS cases: 7.3 Year of events: 1990–1991 | Age category: 50–69 Per 100,000 women: 7.3 (N/R; N/R)
Barchielli, 1999^26^ Year of the study: 1985–1995 Data source: Tuscany cancer registry Country: Italy | Method to diagnose DCIS: Mammography DCIS cases: 16.5 Year of events: 1992–1993 | Age category: 50–69 Per 100,000 women: 16.5 (N/R; N/R)
Barchielli, 1999^26^ Year of the study: 1985–1995 Data source: Tuscany cancer registry Country: Italy | Method to diagnose DCIS: Mammography DCIS cases: 19.2 Year of events: 1994–1995 | Age category: 50–69 Per 100,000 women: 19.2 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 2 Year of events: 1989 | Age category: <50 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 2 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 2 Year of events: 1990 | Age category: <50 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 2 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 2.5 Year of events: 1991 | Age category: <50 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 2.5 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 3 Year of events: 1992 | Age category: <50 Cumulative incidence per 100,000 women(dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 3 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 3.5 Year of events: 1993 | Age category: <50 Cumulative incidence per 100,000 women(dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 3.5 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 3 Year of events: 1994 | Age category: <50 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 3 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 3.5 Year of events: 1995 | Age category: <50 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 3.5 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 3.5 Year of events: 1996 | Age category: <50 Cumulative incidence per 100,000 women (dividing the number of new breast cancer ases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 3.5 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 4 Year of events: 1997 | Age category: <50 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 4 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 9 Year of events: 1989 | Age category: >69 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 9 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 8.5 Year of events: 1990 | Age category: >69 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 8.5 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 9.5 Year of events: 1991 | Age category: >69 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 9.5 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 11 Year of events: 1992 | Age category: >69 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 11 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 13 Year of events: 1993 | Age category: >69 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 13 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 13.5 Year of events: 1994 | Age category: >69 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 13.5 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 15.5 Year of events: 1995 | Age category: >69 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 15.5 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 9.5 Year of events: 1996 | Age category: >69 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 9.5 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 15.5 Year of events: 1997 | Age category: >69 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 15.5 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 8.5 Year of events: 1989 | Age category: 50–69 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 8.5 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 9.5 Year of events: 1990 | Age category: 50–69 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 9.5 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 16 Year of events: 1991 | Age category: 50–69 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 16 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 23 Year of events: 1992 | Age category: 50–69 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 23 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 26 Year of events: 1993 | Age category: 50–69 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 26 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 29 Year of events: 1994 | Age category: 50–69 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 29 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 28.5 Year of events: 1995 | Age category: 50–69 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 28.5 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 31.5 Year of events: 1996 | Age category: 50–69 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 31.5 (N/R; N/R)
Fracheboud, 2004^36^ Year of the study: 1989–1997 Data source: Netherlands Cancer Registry in seven regions that did not start screening activities until 1990 Country: Netherlands | Method to diagnose DCIS: Mammography DCIS cases: 33 Year of events: 1997 | Age category: 50–69 Cumulative incidence per 100,000 women (dividing the number of new breast cancer cases in a certain year by the mid-year female population, which is determined by taking the average of the population on January 1 of that year and the population on January 1 of the following year): 33 (N/R; N/R)
Tabar, 1995^13^ Year of the study: 1977–1990 Data source: The Mammography Department, Central hospital, Falun, Sweden Country: Sweden | Method to diagnose DCIS: Mammography DCIS cases: 28 Year of events: 1977–1990 | Age category: 40–49 Cumulative Incidence rates are age, Histologic Type adjusted per 100000: 11.4 (N/R; N/R)
Tabar, 1995^13^ Year of the study: 1977–1990 Data source: The Mammography Department, Central hospital, Falun, Sweden Country: Sweden | Method to diagnose DCIS: Mammography DCIS cases: 10 Year of events: 1977–1990 | Age category: 40–49 Cumulative Incidence rates are age, Histologic type adjusted per 100,000: 5.1 (N/R; N/R)
Tabar, 1995^13^ Year of the study: 1977–1990 Data source: The Mammography Department, Central hospital, Falun, Sweden Country: Sweden | Method to diagnose DCIS: Mammography DCIS cases: 95 Year of events: 1977–1990 | Age category: 50–74 Cumulative Incidence rates are age, Histologic type adjusted per 100,000: 14.4 (N/R; N/R)
Tabar, 1995^13^ Year of the study: 1977–1990 Data source: The Mammography Department, Central hospital, Falun, Sweden Country: Sweden | Method to diagnose DCIS: Mammography DCIS cases: 36 Year of events: 1977–1990 | Age category: 50–74 Cumulative Incidence rates are age, Histologic type adjusted per 100,000: 7.7 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 0.2 Year of events: 1977–1979 | Age category: 0–39 Cumulative incidence per 100,000 women age-standardized to the world population from 1977–1979: 0.2 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 0.2 Year of events: 1980–1982 | Age category: 0–39 Cumulative incidence per 100,000 women age-standardized to the world population from 1980–1982: 0.2 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 0.2 Year of events: 1983–1985 | Age category: 0–39 Cumulative incidence per 100,000 women age-standardized to the world population from 1983–1985: 0.2 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 0.7 Year of events: 1986–1988 | Age category: 0–39 Cumulative incidence per 100,000 women age-standardized to the world population from 1986–1988: 0.7 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 0.5 Year of events: 1989–1991 | Age category: 0–39 Cumulative incidence per 100,000 women age-standardized to the world population from 1989–1991: 0.5 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 0.8 Year of events: 1992–1994 | Age category: 0–39 Cumulative incidence per 100,000 women age- standardized to the world population from 1992–1994: 0.8 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 3 Year of events: 1977–1979 | Age category: 40–49 Cumulative incidence per 100,000 women age-standardized to the world population from 1977–1979: 3 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 8 Year of events: 1980–1982 | Age category: 40–49 Cumulative incidence per 100,000 women age-standardized to the world population from 1980–1982: 8 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 3.8 Year of events: 1983–1985 | Age category: 40–49 Cumulative incidence per 100,000 women age-standardized to the world population from 1983–1985: 3.8 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 8 Year of events: 1986–1988 | Age category: 40–49 Cumulative incidence per 100,000 women age-standardized to the world population from 1986–1988: 8 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 15.5 Year of events: 1989–1991 | Age category: 40–49 Cumulative incidence per 100,000 women age-standardized to the world population from 1989–1991: 15.5 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 18.8 Year of events: 1992–1994 | Age category: 40–49 Cumulative incidence per 100,000 women age-standardized to the world population from 1992–1994: 18.8 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 2.3 Year of events: 1977–1979 | Age category: 50–69 Cumulative incidence per 100,000 women age-standardized to the world population from 1977–1979: 2.3 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 6 Year of events: 1980–1982 | Age category: 50–69 Cumulative incidence per 100,000 women age-standardized to the world population from 1980–1982: 6 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 4.2 Year of events: 1983–1985 | Age category: 50–69 Cumulative incidence per 100,000 women age-standardized to the world population from 1983–1985: 4.2 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 8.3 Year of events: 1986–1988 | Age category: 50–69 Cumulative incidence per 100,000 women age-standardized to the world population from 1986–1988: 8.3 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 25.3 Year of events: 1989–1991 | Age category: 50–69 Cumulative incidence per 100,000 women age-standardized to the world population from 1989–1991: 25.3 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 23.8 Year of events: 1992–1994 | Age category: 50–69 Cumulative incidence per 100,000 women age-standardized to the world population from 1992–1994: 23.8 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 4 Year of events: 1977–1979 | Age category: 70+ Cumulative incidence per 100,000 women age-standardized to the world population from 1977–1979: 4 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 5 Year of events: 1980–1982 | Age category: 70+ Cumulative incidence per 100,000 women age-standardized to the world population from 1980–1982: 5 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 7.8 Year of events: 1983–1985 | Age category: 70+ Cumulative incidence per 100,000 women age- standardized to the world population from 1983–1985: 7.8 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 6.3 Year of events: 1986–1988 | Age category: 70+ Cumulative incidence per 100,000 women age-standardized to the world population from 1986–1988: 6.3 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 10.5 Year of events: 1989–1991 | Age category: 70+ Cumulative incidence per 100,000 women age-standardized to the world population from 1989–1991: 10.5 (N/R; N/R)
Levi, 1997^19^ Year of the study: 1977–1994 Data source: Cancer Registry of the Swiss Canton of Vaud Country: Switzerland | Method to diagnose DCIS: N/S DCIS cases: 15 Year of events: 1992–1994 | Age category: 70+ Cumulative incidence per 100,000 women age-standardized to the world population from 1992–1994: 15 (N/R; N/R)
Warren, 1999^25^ Year of the study: 1987–1996 Data source: UK National breast screening program Country: UK | Method to diagnose DCIS: Mammography DCIS cases: 11 Year of events: 1987–1989 | Age category: 40–64 Incidence rates are age adjusted per 100,000 population: 129.69 (N/R; N/R)
Warren, 1999^25^ Year of the study: 1987–1996 Data source: UK National breast screening program Country: UK | Method to diagnose DCIS: Mammography DCIS cases: 38 Year of events: 1989–1996 | Age category: 40–64 Incidence rates are age adjusted per 100,000 population: 151.53 (N/R; N/R)

Table F6 Age-adjusted cumulative incidence of DCIS among race subgroups per 100,000 U.S. female population (results from individual studies conducted in the United States are sorted by race subgroup and the year of the events)

Study | DCIS | Race, Cumulative Incidence (95% CI)
Innos, 2003^29^ Year of the study: 1988–1999 Data source: California Cancer Registry | Method to diagnose DCIS: N/S DCIS cases: 30.9 Year of event: annual in 1988–1999 | Race: Asian-Pacific Islander Average annual age-adjusted incidence rates per 100,000 (2000 U.S. female population), 1988–2011: 30.9 (29.6; 32.3)
Zheng, 1997^17^ Year of the study: 1976–92 Data source: Connecticut Tumor Registry | Method to diagnose DCIS: Mammography Year of event: 1973 | Race: Caucasian Age-adjusted incidence rates standardized to the 1970 per 100,000 female population: 2 (N/A; N/A)
Simon, 1993^8^ Year of the study: 1975–1988 Data source: Metropolitan Detroit Cancer Surveillances System | Method to diagnose DCIS: Mammography DCIS cases: 82 Year of event: 1975–76 | Race: Caucasian Age-adjusted incidence rates per 100,000 population using the 1970 U.S. population as the standard: 2.3 (N/A; N/A)
Simon, 1993^8^ Year of the study: 1975–1988 Data source: Metropolitan Detroit Cancer Surveillances System | Method to diagnose DCIS: Mammography DCIS cases: 70 Year of event: 1977–78 | Race: Caucasian Age-adjusted incidence rates per 100,000 population using the 1970 U.S. population as the standard: 2 (N/A; N/A)
Simon, 1993^8^ Year of the study: 1975–1988 Data source: Metropolitan Detroit Cancer Surveillances System | Method to diagnose DCIS: Mammography DCIS cases: 76 Year of event: 1979–80 | Race: Caucasian Age-adjusted incidence rates per 100,000 population using the 1970 U.S. population as the standard: 2.2 (N/A; N/A)
Simon, 1993^8^ Year of the study: 1975–1988 Data source: Metropolitan Detroit Cancer Surveillances System | Method to diagnose DCIS: Mammography DCIS cases: 79 Year of event: 1981–82 | Race: Caucasian Age-adjusted incidence rates per 100,000 population using the 1970 U.S. population as the standard: 2.3 (N/A; N/A)
Simon, 1993^8^ Year of the study: 1975–1988 Data source: Metropolitan Detroit Cancer Surveillances System | Method to diagnose DCIS: Mammography DCIS cases: 103 Year of event: 1983–84 | Race: Caucasian Age-adjusted incidence rates per 100,000 population using the 1970 U.S. population as the standard: 3 (N/A; N/A)
Simon, 1993^8^ Year of the study: 1975–1988 Data source: Metropolitan Detroit Cancer Surveillances System | Method to diagnose DCIS: Mammography DCIS cases: 171 Year of event: 1985–86 | Race: Caucasian Age-adjusted incidence rates per 100,000 population using the 1970 U.S. population as the standard: 5.1 (N/A; N/A)
Simon, 1993^8^ Year of the study: 1975–1988 Data source: Metropolitan Detroit Cancer Surveillances System | Method to diagnose DCIS: Mammography DCIS cases: 295 Year of event: 1987–88 | Race: Caucasian Age-adjusted incidence rates per 100,000 population using the 1970 U.S. population as the standard: 8.7 (N/A; N/A)
Anderson, 2004^35^ Year of the study: 1973–2000 Data source: SEER registries: Connecticut, Hawaii, Iowa, Utah, New Mexico; metropolitan areas of San Francisco, Detroit, Atlanta, and Seattle-Puget Sound | Method to diagnose DCIS: N/S DCIS noncomedo cases: 15,461 Year of event: 1973–2000 | Race: Caucasian Cumulative incidence rate per 100,000 woman-years from 1990–2000: 13.7 (13.504; 14.288)
| Method to diagnose DCIS: N/S DCIS comedo cases: 5,658 Year of event: 1973–2000 | Race: Caucasian Cumulative incidence rate per 100,000 woman-years from 1990–2000: 5 (4.804; 5.392)
Innos, 2002^29^ Year of the study: 1988–1999 Data source: California Cancer Registry | Method to diagnose DCIS: N/S DCIS cases: 45.3 Year of event: annual in 1988–1999 | Race: Caucasian Average annual age-adjusted incidence rates per 100,000 (2000 U.S. female population), 1988–1999: 45.3 (44.7; 45.9)
Zheng, 1997^17^ Year of the study: 1976–92 Data source: Connecticut Tumor Registry | Method to diagnose DCIS: Mammography DCIS cases: Year of event: 1992 | Race: Caucasian Age-adjusted incidence rates standardised to the 1970 per 100,000 female population: 15.5 (N/A; N/A)
Innos, 2002^29^ Year of the study: 1988–1999 Data source: California Cancer Registry | Method to diagnose DCIS: N/S DCIS cases: 21.8 Year of event: annual in 1988–1999 | Race: Hispanic Average annual age-adjusted incidence rates per 100,000 (2000 U.S. female population), 1988–2007: 21.8 (21; 22.7)
Zheng, 1997^17^ Year of the study: 1976–92 Data source: Connecticut Tumor Registry | Method to diagnose DCIS: Mammography DCIS cases: Year of event: 1973–1975 | Race: African American Age-adjusted incidence rates standardized to the 1970 per 100,000 female population: 1.7 (N/A; N/A)
Zheng, 1997^17^ Year of the study: 1976–92 Data source: Connecticut Tumor Registry | Method to diagnose DCIS: Mammography DCIS cases: Year of event: 1991–1992 | Race: African American Age-adjusted incidence rates standardized to the 1970 per 100,000 female population: 9 (N/A; N/A)
Innos, 2002^29^ Year of the study: 1988–1999 Data source: California Cancer Registry | Method to diagnose DCIS: N/S DCIS cases: 35 Year of event: Annual in 1988–1999 | Race: African-American Average annual age-adjusted incidence rates per 100,000 (2000 U.S. female population), 1988–2003: 35 (33.2;3 6.8)
Simon, 1993^8^ Year of the study: 1975–1988 Data source: metropolitan Detroit Cancer Surveillances System | Method to diagnose DCIS: Mammography DCIS cases: 6 Year of event: 1975–76 | Race: African-American Age-adjusted incidence rates per 100,000 population using the 1970 U.S. population as the standard: 0.8 (N/A; N/A)
Simon, 1993^8^ Year of the study: 1975–1988 Data source: metropolitan Detroit Cancer Surveillances System | Method to diagnose DCIS: Mammography DCIS cases: 11 Year of event: 1977–78 | Race: African-American Age-adjusted incidence rates per 100,000 population using the 1970 U.S. population as the standard: 1.4 (N/A; N/A)
Simon, 1993^8^ Year of the study: 1975–1988 Data source: metropolitan Detroit Cancer Surveillances System | Method to diagnose DCIS: Mammography DCIS cases: 14 Year of event: 1979–80 | Race: African-American Age-adjusted incidence rates per 100,000 population using the 1970 U.S. population as the standard: 1.8 (N/A; N/A)
Simon, 1993^8^ Year of the study: 1975–1988 Data source: metropolitan Detroit Cancer Surveillances System | Method to diagnose DCIS: Mammography DCIS cases: 15 Year of event: 1981–82 | Race: African-American Age-adjusted incidence rates per 100,000 population using the 1970 U.S. population as the standard: 1.9 (N/A; N/A)
Simon, 1993^8^ Year of the study: 1975–1988 Data source: metropolitan Detroit Cancer Surveillances System | Method to diagnose DCIS: Mammography DCIS cases: 24 Year of event: 1983–84 | Race: African-American Age-adjusted incidence rates per 100,000 population using the 1970 U.S. population as the standard: 2.7 (N/A; N/A)
Simon, 1993^8^ Year of the study: 1975–1988 Data source: metropolitan Detroit Cancer Surveillances System | Method to diagnose DCIS: Mammography DCIS cases: 31 Year of event: 1985–86 | Race: African-American Age-adjusted incidence rates per 100,000 population using the 1970 U.S. population as the standard: 3.5 (N/A; N/A)
Simon, 1993^8^ Year of the study: 1975–1988 Data source: metropolitan Detroit Cancer Surveillances System | Method to diagnose DCIS: Mammography DCIS cases: 58 Year of event: 1987–88 | Race: African-American Age-adjusted incidence rates per 100,000 population using the 1970 U.S. population as the standard: 6.5 (N/A; N/A)
Anderson, 2004^35^ Year of the study: 1973–2000 Data source: SEER registries: Connecticut, Hawaii, Iowa, Utah, New Mexico; metropolitan areas of San Francisco, Detroit, Atlanta, and Seattle-Puget Sound | Method to diagnose DCIS: N/S DCIS noncomedo cases: 1,632 Year of event: 1973–2000 | Race: African-American Cumulative incidence rate per 100,000 woman-years from 1990–2000: 13.1 (12.512; 13.1784)
| Method to diagnose DCIS: N/S DCIS comedo cases: 478 Year of event: 1973–2000 | Race: African-American Cumulative incidence rate per 100,000 woman-years from 1990–2000: 3.8 (3.408; 3.8588)

Table F7 Association between race and DCIS

Study | Comparison Categories: Estimate (95% CI)
Chen, 2006^82^ Design: Cross-sectional Source: SEER | White (reference group): 1 (1;1) (RR)
Chen, 2006^82^ Design: Cross-sectional Source: SEER | Nonwhite vs. Whites: 0.98 (0.95;1.02) (RR)
Weiss, 1996^64^ Design: Case control study Source: SEER | White (reference group): 1 (1;1) (OR)
Weiss, 1996^64^ Design: Case control study Source: SEER | African American vs. White: 1.65 (1;2.9) (OR)
Anderson, 2004^35^ Design: Prospective cohort study Source: SEER | DCIS non comedo in White (reference group): 1 (N/A;N/A) (rate ratio)
Anderson, 2004^35^ Design: Prospective cohort study Source: SEER | DCIS non comedo in Black vs. White: 1 (N/A;N/A) (rate ratio)
Anderson, 2004^35^ Design: Prospective cohort study Source: SEER | DCIS comedo in White (reference group): 1 (N/A;N/A) (rate ratio)
Anderson, 2004^35^ Design: Prospective cohort study Source: SEER | DCIS comedo in Black vs. White: 0.7 (N/A; N/A) (rate ratio)
Elmore, 1998^66^ Design: Well-designed nested case-control study (retrospective cohort) Source: Cancer Center Registry (CT) Adjusted for age | Black vs. White: 0.45 (0.22; 0.9) (OR)
Kerlikowske, 2005^47^ Design: Retrospective cohort Source: Cancer Registry (CA) | White vs. Chinese: 1.0625 (N/A; N/A) (RR)
Kerlikowske, 2005^47^ Design: Retrospective cohort Source: Cancer Registry (CA) | White vs. Filipino: 1 (N/A; N/A) (RR)
Kerlikowske, 2005^47^ Design: Retrospective cohort Source: Cancer Registry (CA) | Chinese vs. Filipino: 0.941 (N/A; N/A) (RR)
Elmore, 1998^66^ Design: Well-designed nested case-control study (retrospective cohort) Source: Cancer Center Registry (CT) Crude | Black vs. White: 0.45 (0.23; 0.89) (OR)
Elmore, 1998^66^ Design: Well-designed nested case-control study (retrospective cohort) Source: Cancer Center Registry (CT) Adjusted for Income | Black vs. White: 0.49 (0.23; 1.02) (OR)
Elmore, 1998^66^ Design: Well-designed nested case-control study (retrospective cohort) Source: Cancer center Registry (CT) Adjusted for insurance | Black vs. White: 0.5 (0.25;1.02) (OR)
Elmore, 1998^66^ Design: Well-designed nested case-control study (retrospective cohort) Source: Cancer Center Registry (CT) Adjusted for method of detection | Black vs. White: 0.43 (0.2; 0.92) (OR)
Elmore, 1998^66^ Design: Well-designed nested case-control study (retrospective cohort) Source: Cancer Center Registry (CT) Adjusted for insurance, income, and method of detection | Black vs. White: 0.5 (0.22; 1.17) (OR)

Table F8 Association between external hormone use and DCIS

Study | Comparison Groups: Estimate (95% CI)
| Hormone replacement therapy
Gapstur, 1999^69^ Design: Prospective cohort study Source: IWHS | Duration of ever use of hormone replacement therapy: Never (reference group): 1 (1;1) (RR)
Gapstur, 1999^69^ Design: Prospective cohort study Source: IWHS | Duration of ever use of hormone replacement therapy: <5 years vs. never: 1.08 (0.77; 1.52) (RR)
Gapstur, 1999^69^ Design: Prospective cohort study Source: IWHS | Duration of ever use of hormone replacement therapy: >5 years vs. never: 1.1 (0.68; 1.77) (RR)
Gapstur, 1999^69^ Design: Prospective cohort study Source: IWHS | Past hormone user <5 years vs. never: 0.91 (0.61; 1.34) (HR)
Gapstur, 1999^69^ Design: Prospective cohort study Source: IWHS | Past hormone user >5 years vs. never: 0.29 (0.07; 1.18) (HR)
Gapstur, 1999^69^ Design: Prospective cohort study Source: IWHS | Current hormone use <5 years vs. never: 0.94 (0.41; 2.16) (HR)
Gapstur, 1999^69^ Design: Prospective cohort study Source: IWHS | Current hormone user >5 years vs. never: 1.35 (0.77; 2.36) (HR)
Claus, 2001^71^ Design: Case control study Source: Cancer Center Registry (CT) | Hormone replacement therapy use: never (reference group): 1 (1; 1) (OR)
Claus, 2001^71^ Design: Case control study Source: Cancer Center Registry (CT) | Hormone replacement therapy use (ever versus never): 1.22 (0.99; 1.52) (OR)
Kerlikowske, 2003^77^ Design: Prospective cohort study Source: Breast Cancer Surveillance Consortium | Estrogen and Progestin Users for >5 years vs. nonusers: 1.41 (1.24; 1.6) (RR)
Kerlikowske, 2003^77^ Design: Prospective cohort study Source: Breast Cancer Surveillance Consortium | Estrogen and Progestin Users for <5 years vs. nonuser: 0.77 (0.62; 0.96) (RR)
Kerlikowske, 2003^77^ Design: Prospective cohort study Source: Breast Cancer Surveillance Consortium | Estrogen-only users vs. nonusers: 0.98 (0.89; 1.07) (RR)
Reeves, 2006^81^ Design: Prospective cohort study Source: UK Central Registers | Hormonal therapy current use vs. never use: 1.56 (1.38; 1.75) (RR)
Reeves, 2006^81^ Design: Prospective cohort study Source: UK Central Registers | Hormonal therapy past use vs. never use: 1.19 (1.03; 1.38) (RR)
Trentham-Dietz, 2000^70^ Design: Case control study Source: Cancer Registry (WI) | Use of postmenopausal hormones never use (reference group): 1 (N/A;N/A) (OR)
Trentham-Dietz, 2000^70^ Design: Case control study Source: Cancer Registry (WI) | Use of postmenopausal hormones time since last use (yearsr) <5 vs. never use: 2.03 (1.24; 3.34) (OR)
Trentham-Dietz, 2000^70^ Design: Case control study Source: Cancer Registry (WI) | Use of postmenopausal hormones time since last use (years) ≥5 vs. never use: 1.83 (1.05; 3.2) (OR)
| Oral contraceptives
Vamre, 2006^83^ Design: Cross-sectional Source: WHO study | Age >35 years at first use of oral contraceptive vs. never use: 2.15 (1.05; 4.4) (prevalence rate ratio)
Claus, 2001^71^ Design: Case control study Source: Cancer center Registry (CT) | Oral contraceptive use (ever vs. never): No (reference group): 1 (1; 1) (OR)
Claus, 2001^71^ Design: Case control study Source: Cancer center Registry (CT) | Oral contraceptive use (ever vs. never): Yes vs. no: 0.92 (0.72; 1.18) (OR)
Nichols, 2007^86^ Design: Case control study Source: Collaborative Breast Cancer Study | Oral contraceptive use: never (reference group): 1 (1; 1) (OR)
Nichols, 2007^86^ Design: Case control study Source: Collaborative Breast Cancer Study | Oral contraceptive use: ever vs. never: 1.15 (1.01; 1.31) (OR)
Nichols, 2007^86^ Design: Case control study Source: Collaborative Breast Cancer Study | Age started OC use: Age 19 or younger vs. never: 1.34 (1.06; 1.68) (OR)
Nichols, 2007^86^ Design: Case control study Source: Collaborative Breast Cancer Study | Age started OC use: Age 20–23 vs. never: 1.19 (1.01; 1.41) (OR)
Nichols, 2007^86^ Design: Case control study Source: Collaborative Breast Cancer Study | Age started OC use: Age 24–28 vs. never: 1.06 (0.86; 1.31) (OR)
Nichols, 2007^86^ Design: Case control study Source: Collaborative Breast Cancer Study | Age started OC use: >29 vs. never: 1.07 (0.85; 1.34) (OR)
Nichols, 2007^86^ Design: Case control study Source: Collaborative Breast Cancer Study | Duration of OC use: 1–1.9 years vs. never: 1.09 (0.91; 1.31) (OR)
Nichols, 2007^86^ Design: Case control study Source: Collaborative Breast Cancer Study | Duration of OC use: 2–4.4 years vs. never: 1.28 (1.07; 1.52) (OR)
Nichols, 2007^86^ Design: Case control study Source: Collaborative Breast Cancer Study | Duration of OC use: 4.5–8.9 years vs. never: 1.14 (0.92; 1.4) (OR)
Nichols, 2007^86^ Design: Case control study Source: Collaborative Breast Cancer Study | Duration of OC use: >9 years vs. never: 1.08 (0.89; 1.33) (OR)
Nichols, 2007^86^ Design: Case control study Source: Collaborative Breast Cancer Study | Time since first OC use: <23 years vs. never: 1.25 (0.98; 1.6) (OR)
Nichols, 2007^86^ Design: Case control study Source: Collaborative Breast Cancer Study | Time since first OC use: 23–27 years vs. never: 1.14 (0.94; 1.38) (OR)
Nichols, 2007^86^ Design: Case control study Source: Collaborative Breast Cancer Study | Time since first OC use: 28–32 years vs. never: 1.16 (0.98; 1.38) (OR)
Nichols, 2007^86^ Design: Case control study Source: Collaborative Breast Cancer Study | Time since first OC use: >32 years vs. never: 1.08 (0.86; 1.35) (OR)
Nichols, 2007^86^ Design: Case control study Source: Collaborative Breast Cancer Study | Time since last OC use: <15 years vs. never: 1.21 (0.97; 1.5) (OR)
Nichols, 2007^86^ Design: Case control study Source: Collaborative Breast Cancer Study | Time since last OC use: 16–20 years vs. never: 1.18 (0.96; 1.46) (OR)
Nichols, 2007^86^ Design: Case control study Source: Collaborative Breast Cancer Study | Time since last OC use: 21–25 years vs. never: 1.27 (1.07; 1.53) (OR)
Nichols, 2007^86^ Design: Case control study Source: Collaborative Breast Cancer Study | Time since last OC use: 26+ years vs. never: 1.01 (0.84; 1.21) (OR)
Nichols, 2007^86^ Design: Case control study Source: Collaborative Breast Cancer Study | OC use in relation to first full-term: never users: 1 (1; 1) (OR)
Nichols, 2007^86^ Design: Case control study Source: Collaborative Breast Cancer Study | OC use in relation to first full-term: use before pregnancy vs. never: 1.19 (0.99; 1.44) (OR)
Nichols, 2007^86^ Design: Case control study Source: Collaborative Breast Cancer Study | OC use in relation to first full-term: use after pregnancy vs. never: 1.09 (0.92; 1.28) (OR)
Trentham-Dietz, 2000^70^ Design: Case control study Source: Cancer Registry (WI) | Use of oral contraceptives never (reference group): 1 (N/A; N/A) (OR)
Trentham-Dietz, 2000^70^ Design: Case control study Source: Cancer Registry (WI) | Use of oral contraceptives ever vs. never: 1.25 (0.89; 1.77) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Contraceptive use never (reference group): 1 (1; 1) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Contraceptive use ever vs. never use contraceptive: 1 (0.8; 1.2) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Contraceptive use current vs. never use contraceptive: 0.6 (0.3; 1.3) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Contraceptive use former vs. never use contraceptive: 1 (0.8; 1.3) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Ever use oral contraceptive and family history none vs. never use contraceptive: 0.9 (0.7; 1.2) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Ever use oral contraceptive and family history first degree vs. never use contraceptive: 0.9 (0.5; 1.7) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Ever use oral contraceptive and family history second degree vs. never use contraceptive: 1.3 (0.7; 2.2) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Ever use oral contraceptive and family history any vs. never use contraceptive: 1.1 (0.7; 1.7) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Duration of use <1 year vs. never use contraceptive: 0.8 (0.5; 1.1) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Duration of use 1 to <5 years vs. never use contraceptive: 1 (0.8; 1.4) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Duration of use 5 to <10 years vs. never use contraceptive: 1.1 (0.7; 1.5) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Duration of use ≥10 year vs. never use contraceptive: 0.9 (0.6; 1.5) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Duration of high estrogen use <1 year vs. never use contraceptive: 1 (0.8; 1.3) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Duration of high estrogen use 1 to <5 years vs. never use contraceptive: 1 (0.7; 1.5) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Duration of high estrogen use ≥5 years vs. never use contraceptive: 1 (0.6; 1.6) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Age at first use <20 years vs. never use contraceptive: 0.7 (0.4; 1.1) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Age at first use 20–24 years vs. never use contraceptive: 1.1 (0.8; 1.4) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Age at first use 25–29 years vs. never use contraceptive: 1 (0.7; 1.4) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Age at first use 30–34 years vs. never use contraceptive: 0.9 (0.6; 1.4) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Age at first use ≥35 years vs. never use contraceptive: 1.2 (0.6; 2.3) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Time since last use current vs. never use contraceptive: 0.6 (0.3; 1.3) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Time since last use 13 months-5 years vs. never use contraceptive: 1 (0.4; 2.2) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Time since last use 5–10 years vs. never use contraceptive: 0.9 (0.5; 1.8) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Time since last use 10–15 years vs. never use contraceptive: 1 (0.6; 1.7) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Time since last use ≥15 years vs. never use contraceptive: 1 (0.8; 1.3) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Estrogen type low dose only vs. never use contraceptive: 0.7 (0.5; 1.1) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Estrogen type high dose only vs. never use contraceptive: 1 (0.7; 1.4) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Estrogen by progestin type estrane low dose estrogen only vs. never use contraceptive: 0.7 (0.4; 1.2) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Estrogen by progestin type estrane high dose estrogen only vs. never use contraceptive: 1 (0.7; 1.4) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Gonane low dose estrogen only vs. never use contraceptive: 0.8 (0.4; 1.5) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Gonane high dose estrogen only vs. never use contraceptive: 1.3 (0.8; 2.2) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Progestin type estrane vs. never use contraceptive: 0.9 (0.7; 1.2) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Progestin type gonane vs. never use contraceptive: 1.1 (0.8; 1.7) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and contraceptive use never (reference group): 1 (N/A; N/A) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and contraceptive use ever vs. never use contraceptive: 1 (0.6; 1.6) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and contraceptive use current vs. never use contraceptive: 0.4 (0.2; 1.1) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and contraceptive use former vs. never use contraceptive: 1.1 (0.7; 1.7) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and ever use oral contraceptive and family history none vs. never use contraceptive: 0.7 (0.4; 1.2) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and ever use oral contraceptive and family history first degree vs. never use contraceptive: 2.3 (0.7; 8) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and ever use oral contraceptive and family history second degree vs. never use contraceptive: 1.6 (0.6; 4.2) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and ever use oral contraceptive and family history any vs. never use dontraceptive: 1.8 (0.8; 4.1) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and duration of use <1 year vs. never use contraceptive: 0.9 (0.5; 1.8) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and duration of use 1 to <5 years vs. never use contraceptive: 0.9 (0.5; 1.6) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and duration of use 5 to <10 years vs. never use Contraceptive: 0.9 (0.5; 1.7) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and Duration of use ≥10 year vs. never use contraceptive: 1.1 (0.5; 2.2) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and duration of high estrogen use <1 year vs. never use contraceptive: 0.9 (0.6; 1.5) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and duration of high estrogen use 1 to <5 years vs. never use contraceptive: 1.1 (0.6; 2.2) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and duration of high estrogen use ≥5 years vs. never use contraceptive: 1.2 (0.6; 2.5) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and age at first use <20 years vs. never use contraceptive: 0.7 (0.4; 1.3) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and age at first use 20–24 years vs. never use contraceptive: 1.1 (0.7; 1.8) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and age at first use 25–29 years vs. never use contraceptive: 1.4 (0.7; 2.8) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and age at first use 30–34 years vs. never use contraceptive: 1.1 (0.4; 3.6) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and age at first use ≥35 years vs. never use contraceptive: 0.9 (0.1; 7.5) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and time since last use current vs. never use contraceptive: 0.4 (0.2; 1.1) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and time since last use 13 months–5 years vs. never use contraceptive: 1 (0.4; 2.7) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and time since last use 5–10 years vs. never use contraceptive: 1 (0.4; 2.4) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and time since last use 10–15 years vs. never use contraceptive: 0.9 (0.5; 1.9) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and time since last use ≥15 years vs. never use contraceptive: 1.1 (0.7; 1.8) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and progestin type estrane vs. never use contraceptive: 0.9 (0.5; 1.5) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and progestin type gonane vs. never use contraceptive: 1.4 (0.7; 2.5) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and estrogen type low dose only vs. never use contraceptive: 0.6 (0.4; 1.2) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Pre-menopausal and estrogen type high dose only vs. never use contraceptive: 1.5 (0.8; 2.7) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Post-menopausal and contraceptive use never vs. never use contraceptive: 1 (N/A; N/A) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Post-menopausal and contraceptive use ever vs. never use contraceptive: 1 (0.7; 1.4) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Post-menopausal and contraceptive use current vs. never use contraceptive: 1.4 (0.4; 4.5) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Post-menopausal and contraceptive use former vs. never use contraceptive: 1 (0.8; 1.4) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Post-menopausal and ever use oral contraceptive and family history none vs. never use contraceptive: 1.1 (0.7; 1.5) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Post-menopausal and ever use oral contraceptive and family history first degree vs. never use contraceptive: 0.8 (0.4; 1.5) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Post-menopausal and ever use oral contraceptive and family history 2nd degree vs. never use contraceptive: 1.1 (0.5; 2.2) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Post-menopausal and ever use oral contraceptive and family history any vs. never use contraceptive: 0.9 (0.6; 1.6) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Post-menopausal and duration of use <1 year vs. never use contraceptive: 0.7 (0.4; 1) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Post-menopausal and duration of use 1 to <5 years vs. never use contraceptive: 1.1 (0.8; 1.6) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Post-menopausal and duration of use 5 to <10 years vs. never use contraceptive: 1.5 (0.9; 2.7) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Post-menopausal and duration of use ≥10 year vs. never use contraceptive: 0.8 (0.4; 1.6) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Post-menopausal and duration of high estrogen use <1 year vs. never use dontraceptive: 1 (0.8; 1.4) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Post-menopausal and duration of high estrogen use 1 to <5 years vs. never use contraceptive: 1.1 (0.6; 1.8) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Post-menopausal and duration of high estrogen use ≥5 years vs. never use contraceptive: 0.9 (0.5; 1.7) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Post-menopausal and age at first use <20 years vs. never use contraceptive: 0.9 (0.4; 2) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Post-menopausal and age at first use 20–24 years vs. never use contraceptive: 1.2 (0.8; 2) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Post-menopausal and age at first use 25–29 years vs. never use contraceptive: 0.9 (0.6; 1.4) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Post-menopausal and age at first use 30–34 years vs. never use contraceptive: 0.9 (0.5; 1.6) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Post-menopausal and age at first use ≥35 years vs. never use contraceptive: 1.1 (0.6; 2.3) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Time since last use current vs. never use contraceptive: 1.4 (0.4; 4.5) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Time since last use 13 months–5 years vs. never use contraceptive: N/A (N/A; N/A) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Time since last use 5–10 years vs. never use contraceptive: N/A (N/A; N/A) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Time since last use 10–15 years vs. never use contraceptive: N/A (N/A; N/A) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Post-menopausal and time since last use ≥15 years vs. never use contraceptive: 1 (0.7; 1.3) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Progestin type estrane vs. never use contraceptive: 1 (0.7; 1.5) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Progestin type gonane vs. never use contraceptive: 1.3 (0.6; 2.5) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Estrogen type low dose only vs. never use contraceptive: 1.2 (0.6; 2.4) (OR)
Claus, 2003^76^ Design: Case control study Source: Cancer Center Registry (CT) | Estrogen type high dose only vs. never use contraceptive: 1 (0.6; 1.5) (OR)

Table F9 Association between age at first birth and DCIS

Study | Comparison Groups: Estimate (95% CI)
| Age at first live birth (years)
Weiss, 1996^64^ Design: Case control study Source: SEER | Age at first full-term birth: <20 (reference group): 1 (1; 1) (OR)
Weiss, 1996^64^ Design: Case control study Source: SEER | Age at first full-term birth: 20–24 vs.<20: 0.89 (0.5; 1.7) (OR)
Weiss, 1996^64^ Design: Case control study Source: SEER | Age at first full-term birth: 25–29 vs. <20: 1.11 (0.6; 2.2) (OR)
Weiss, 1996^64^ Design: Case control study Source: SEER | Age at first full-term birth: >30 vs. <20: 1.23 (0.6; 2.5) (OR)
Gapstur, 1999^69^ Design: Prospective cohort study Source: IWHS | Age at first birth (for porous women only): <20 (reference group): 1 (1; 1) (RR)
Gapstur, 1999^69^ Design: Prospective cohort study Source: IWHS | Age at first birth (for porous women only): 21–29 vs. <20: 1.25 (0.9; 1.73) (RR)
Gapstur, 1999^69^ Design: Prospective cohort study Source: IWHS | Age at first birth (for porous women only): >30 vs. <20: 1.92 (1.1; 3.37) (RR)
Trentham-Dietz, 2000^70^ Design: Case control study Source: Cancer Registry (WI) | Age at first full-term birth <20 (reference group): 1 (N/A; N/A) (OR)
Trentham-Dietz, 2000^70^ Design: Case control study Source: Cancer Registry (WI) | Age at first full-term birth 20–24 vs. <20: 1.14 (0.73; 1.77) (OR)
Trentham-Dietz, 2000^70^ Design: Case control study Source: Cancer Registry (WI) | Age at first full-term birth 25–29 vs. <20: 1.3 (0.79; 2.15) (OR)
Trentham-Dietz, 2000^70^ Design: Case control study Source: Cancer Registry (WI) | Age at first full-term birth ≥30 or nulliparous vs. <20: 1.88 (1.16; 3.06) (OR)
Claus, 2001^71^ Design: Case control study Source: Cancer Center Registry (CT) | Age at first live birth: <20 (reference group): 1 (1; 1) (OR)
Claus, 2001^71^ Design: Case control study Source: Cancer Center Registry (CT) | Age at first live birth: 20–29 vs. <20: 1.68 (1.17; 2.43) (OR)
Claus, 2001^71^ Design: Case control study Source: Cancer Center Registry (CT) | Age at first live birth: >30 vs. <20: 1.77 (1.12; 2.81) (OR)
Claus, 2001^71^ Design: Case control study Source: Cancer Center Registry (CT) | Age at first live birth: per 1 year: 1.02 (1; 1.05) (OR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 12–19 vs. 20–24: 0.81 (0.62; 1.04) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 20–24 (reference group): 1 (1; 1) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 25–29 vs. 20–24: 1.22 (1.01; 1.47) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 30–34 vs. 20–24: 1.43 (1.06; 1.93) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 35+ vs. 20–24: 1.22 (0.68; 2.21) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Uniparous 20 years at first birth vs. nulliparous: 0.89 (0.84; 0.95) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Uniparous 24years at first birth vs. nulliparous: 0.93 (0.68; 1.28) (RR)
Granström, 2008^88^ Design: Prospective cohort study Source: Second Generation Swedish Family Register renamed to Multigeneration Register linked to the Swedish Cancer Registry (1958–2004) to make the Family-Cancer Database (MigMed2) | Age at first birth: 13–20 vs. 30+ 0.73 (0.63; 0.86) (RR)
| Age at first birth: 21–24 vs. 30+ 0.78 (0.68; 0.90) (RR)
| Age at first birth: 25–29 vs. 30+ 0.88 (0.77; 1.01) (RR)
| Age at first birth: 30+ (reference group) 1.00 (1.00; 1.00) (RR)
| Age at first live birth and DCIS comedo type
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 12–19 vs. 20–24: 0.69 (0.44; 1.09) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 20–24 (reference group): 1 (1; 1) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 25–29 vs. 20–24: 1.38 (1.02; 1.88) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 30+ vs. 20–24: 1.63 (1.05; 2.52) (RR)
| Age at first live birth and DCIS non comedo type
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 12–19 vs. 20–24: 0.85 (0.62; 1.15) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 20–24 (reference group): 1 (1; 1) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 25–29 vs. 20–24: 1.14 (0.9; 1.44) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 30+ vs. 20–24: 1.27 (0.87; 1.83) (RR)
| Age at first live birth and DCIS with Diameter <10mm
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 12–19 vs. 20–24: 1.03 (0.6; 1.76) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 20–24 (reference group): 1 (1; 1) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 25–29 vs. 20–24: 1.27 (0.83; 1.96) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 30+ vs. 20–24: 0.88 (0.42; 1.84) (RR)
| Age at first live birth and DCIS with Diameter >10mm
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 12–19 vs. 20–24: 0.53 (0.32; 0.86) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 20–24 (reference group): 1 (1; 1) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 25–29 vs. 20–24: 1.29 (0.96; 1.73) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 30+ vs. 20–24: 1.92 (1.28; 2.88) (RR)
| Age at first live birth and Micro-focal DCIS
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 12–19 vs. 20–24: 1.19 (0.77; 1.84) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 20–24 (reference group): 1 (1; 1) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 25–29 vs. 20–24: 1.09 (0.74; 1.6) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Age at first birth: 30+ vs. 20–24: 0.93 (0.48; 1.79) (RR)

Table F10 Association between parity and DCIS

Study | Comparison Groups: Estimate (95% CI)
Weiss, 1996^64^ Design: Case control study Source: SEER | Parous: yes (reference group): 1 (1; 1) (OR)
Weiss, 1996^64^ Design: Case control study Source: SEER | Parous: no vs. yes: 2.31 (1.3; 4.2) (OR)
Weiss, 1996^64^ Design: Case control study Source: SEER | Number of full time births: 1: 1 (1; 1) (OR)
Weiss, 1996^64^ Design: Case control study Source: SEER | Number of full time births: 2 vs. 1: 0.8 (0.5; 1.3) (OR)
Weiss, 1996^64^ Design: Case control study Source: SEER | Number of full time births: 3 vs. 1: 0.54 (0.3; 1) (OR)
Weiss, 1996^64^ Design: Case control study Source: SEER | Number of full time births:>4 vs. 1: 0.47 (0.2; 1.2) (OR)
Kerlikowskec, 1997^65^ Design: Cross-sectional Source: Screening Program (CA) | Nulliparous or >30 years old at birth of first child among 30–49 years old: 1.4 (0.8; 2.7) (OR)
Kerlikowskec, 1997^65^ Design: Cross-sectional Source: Screening Program (CA) | Nulliparous or >30 years old at birth of first child among >50 years old: 2.3 (1.3; 3.8) (OR)
Kerlikowskec, 1997^65^ Design: Cross-sectional Source: Screening Program (CA) | Parity: 0 (reference group): 1 (1; 1) (RR)
Kerlikowskec, 1997^65^ Design: Cross-sectional Source: Screening Program (CA) | Parity: 1–2 childbirths vs. 0: 0.98 (0.57; 1.68) (RR)
Kerlikowskec, 1997^65^ Design: Cross-sectional Source: Screening Program (CA) | Parity: >3 vs. 0: 0.87 (0.52; 1.46) (RR)
Claus, 2001^71^ Design: Case control study Source: Cancer Center Registry (CT) | Number of full-term pregnancies: No (reference group): 1 (1; 1) (OR)
Claus, 2001^71^ Design: Case control study Source: Cancer Center Registry (CT) | Number of full-term pregnancies: Yes, per full-term pregnancy vs. no: 0.86 (0.8; 0.93) (OR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Nulliparous (reference group): 1 (1; 1) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Parous vs. nulliparous: 1.05 (0.83; 1.33) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Number of births: 1 (reference group): 1 (1; 1) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Number of births: 2 vs. 1: 1 (0.8; 1.24) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Number of births: 3 vs. 1: 0.93 (0.72; 1.21) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Number of births: 4+ vs. 1: 0.66 (0.44; 0.98) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | RR per birth: 1.03 (0.93; 1.14) (RR)
Granström, 2008^88^ Design: Prospective cohort study Source: Second Generation Swedish Family Register renamed to Multigeneration Register linked to the Swedish Cancer Registry (1958–2004) to make the Family-Cancer Database (MigMed2) | Parity: 0 vs. +3 1.20 (1.01; 1.43) (RR)
| Parity: 1 vs. +3 1.16 (1.02; 1.33) (RR)
| Parity: 2 vs. +3 DCIS 1.12 (1.01; 1.25) (RR)
| Parity: 3+ (reference group) DCIS 1.00 (1.00; 1.00) (RR)
| DCIS comedo type
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Nulliparous (reference group): 1 (1; 1) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Parous vs. nulliparous: 1.05 (0.77; 1.42) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Number of births: 1 (reference group): 1 (1; 1) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Number of births: 2 vs. 1: 0.82 (0.58; 1.15) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Number of births: 3 vs. 1: 0.72 (0.48; 1.08) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | RR per birth: 0.96 (0.81; 1.13) (RR)
| DCIS non comedo type
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Nulliparous (reference group): 1 (1; 1) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Parous vs. nulliparous: 0.99 (0.67; 1.46) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Number of births: 1 (reference group): 1 (1; 1) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Number of births: 2 vs. 1: 1.15 (0.86; 1.54) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Number of births: 3 vs. 1: 0.99 (0.71; 1.37) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | RR per birth: 1.07 (0.95; 1.21) (RR)
| DCIS with diameter <10mm
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Nulliparous (reference group): 1 (1; 1) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Parous vs. nulliparous: 1.46 (0.77; 2.79) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Number of births: 1 (reference group): 1 (1; 1) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Number of births: 2 vs. 1: 0.6 (0.38; 0.96) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Number of births: 3 vs. 1: 0.61 (0.36; 1.03) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | RR per birth: 0.89 (0.71; 1.13) (RR)
| DCIS with diameter >10mm
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Nulliparous (reference group): 1 (1; 1) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Parous vs. nulliparous: 0.87 (0.61; 1.25) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Number of births: 1 (reference group): 1 (1; 1) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Number of births: 2 vs. 1: 1.13 (0.81; 1.6) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Number of births: 3 vs. 1: 0.82 (0.54; 1.23) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | RR per birth: 0.98 (0.83; 1.15) (RR)
| Micro-focal DCIS
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Nulliparous (reference group): 1 (1; 1) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Parous vs. nulliparous: 1.22 (0.73; 2.04) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Number of births: 1 (reference group): 1 (1; 1) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Number of births: 2 vs. 1: 1.15 (0.73; 1.82) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | Number of births: 3 vs. 1: 0.83 (0.49; 1.4) (RR)
Wohlfahrt, 2004^79^ Design: Prospective cohort study Source: Danish Breast Cancer Registry | RR per birth: 0.99 (0.82; 1.2) (RR)

Table F11 Association between body composition and DCIS

Study | Comparison Categories of Body Mass Index, kg/m2: Estimate (95% CI)
| Body mass index, kg/m2
Weiss, 1996^64^ Design: Case control study Source: SEER | 22–24.59 vs.<22: 0.55 (0.4; 0.9) (OR)
Weiss, 1996^64^ Design: Case control study Source: SEER | 24.6–29.02 vs.<22: 0.57 (0.4; 0.9) (OR)
Weiss, 1996^64^ Design: Case control study Source: SEER | >29.03 vs. <22: 0.41 (0.2; 0.7) (OR)
Gapstur, 1999^69^ Design: Prospective cohort study Source: IWHS | 24.3–28.3 vs. <24.3: 1.11 (0.77; 1.61) (RR)
Gapstur, 1999^69^ Design: Prospective cohort study Source: IWHS | >28.3 vs. <24.3: 1.18 (0.82; 1.7) (RR)
| Body mass index at age categories
Gapstur, 1999^69^ Design: Prospective cohort study Source: IWHS | 20.2–22.3 vs.<20.2 at age 18: 1.38 (0.98; 1.95) (RR)
Gapstur, 1999^69^ Design: Prospective cohort study Source: IWHS | >22.3 vs.<20.2 at age 18: 0.73 (0.49; 1.1) (RR)
Kerlikowskec, 1997^65^ Design: Cross-sectional Source: Screening Program (CA) | >25 among 30–49 years old: 0.4 (0.2; 0.9) (OR)
Kerlikowskec, 1997^65^ Design: Cross-sectional Source: Screening Program (CA) | >25 among >50 years old: 1.1 (0.6;1.9) (OR)
| Waist-to-hip ratio
Gapstur, 1999^69^ Design: Prospective cohort study Source: IWHS | 0.79–0.87 vs. <0.79: 1.09 (0.76; 1.58) (RR)
Gapstur, 1999^69^ Design: Prospective cohort study Source: IWHS | >0.87 vs. <0.79: 1.12 (0.77; 1.62) (RR)

Table F12 Incidence of DCIS among women with familial risk in breast cancer surveillance trials (modified from Brekelmans, 2001)89

Author | Sample | Country | Years | Followup | % of DCIS/All Breast Cancer | n DCIS | Rate of DCIS (%) | Low 95% CI | Upper 95% CI
Saetersdal, 1996^90^ | 537 | Norway | 42.5 | | 11 | 1 | 0.2 | 0 | 1.3
Moller, 1996^91^ | 1194 | Norway | 42.9 | 1.8 years | 30 | 7 | 0.6 | 0.3 | 1.2
Chart, 1997^92^ | 1044 | Canada | 39.5/42.7 | 21.9 months | 39 | 9 | 0.9 | 0.4 | 1.6
Lalloo, 1998^93^ | 1259 | UK | 39.1 | 30 months | 23 | 3 | 0.2 | 0.1 | 0.7
Kollias, 1998^94^ | 1371 | UK | 41 | 22 months | 21 | 6 | 0.4 | 0.2 | 1
Tilanus-Linthorst, 2000^95^ | 678 | The Netherlands | 42.9/43.3 | 3.3 years | 19 | 10 | 1.5 | 0.8 | 2.7
Brekelmans, 1996^96^ | 25,632 | The Netherlands | 38 | 36 months | 11 | 15 | 0.1 | 0 | 0.1

Table F13 DCIS in different populations at high risk of breast cancer

Author | Country | Population | Age | Followup | N | DCIS | %DCIS | Low 95% CI | Upper 95% CI
Komenaka, 2004^97^ | USA | BRCA mutation carriers +family history | 46 (32–59) | 7 years | 22 | 2 | 9.1 | 2.3 | 30
Hoogerbrugg, 2006^98^ | The Netherlands | High family history who underwent prophylactic mastectomy, BRCA carriers | 40 ± 9 | | 82 | 9 | 11 | 5.8 | 19.8
Hoogerbrugg, 2006^98^ | The Netherlands | High family history who underwent prophylactic mastectomy, non BRCA carriers | 44 ± 8 | | 24 | 17 | 70.8 | 50.2 | 85.4
Hoogerbrugg, 2006^98^ | The Netherlands | High family history who underwent prophylactic mastectomy | 44 ± 9 | | 106 | 11^*^ | 10.4 | 5.8 | 17.8
Brekelmans, 2001^89^ | The Netherlands | Family history of breast cancer, dense mammographic breast tissue and/or BRCA1/2 gene carriers (breast cancer risk >15%) | 38 (21–70) | 3 years | 1,198 | 4 | 0.3 | 0.1 | 0.9
Brekelmans, 2001^89^ | The Netherlands | BRCA1/2 gene mutation carriers | 38 (21–70) | 3 years | 128 | 0 | 0.4 | 0 | 5.9
Brekelmans, 2001^89^ | The Netherlands | High risk | 38 (21–70) | 3 years | 621 | 4 | 0.6 | 0.2 | 1.7
Brekelmans, 2001^89^ | The Netherlands | Moderate risk | 38 (21–70) | 3 years | 449 | 0 | 0.1 | 0 | 1.8

* occult cancer

Table F14 Association between family history, genetic predisposition, and DCIS

Study | Comparison Groups: Estimate (95% CI)
Gapstur, 1999^69^ Design: Prospective cohort study Source: IWHS | Family history of breast cancer in a first-degree relative: No (reference group): 1 (1; 1) (RR)
Gapstur, 1999^69^ Design: Prospective cohort study Source: IWHS | Family history of breast cancer in a first-degree relative: Yes vs. no: 2.09 (1.46; 3) (RR)
Kerlikowskec, 1997^65^ Design: Cross-sectional Source: Screening Program (CA) | Family history of breast cancer as least on first degree relative (mother, sister, or daughter): 2.4 (1.1; 4.9) (OR)
Kerlikowskec, 1997^65^ Design: Cross-sectional Source: Screening Program (CA) | Family history of breast cancer as least on first degree relative (mother, sister, or daughter) among >50 years old: 2.2 (1; 4.2) (OR)
Claus, 2001^71^ Design: Case control study Source: Cancer center Registry (CT) | Family history of breast cancer: No (reference group): 1 (1; 1) (OR)
Claus, 2001^71^ Design: Case control study Source: Cancer center Registry (CT) | Family history of breast cancer: Yes vs. no: 1.48 (1.19; 1.85) (OR)
Weiss, 199^64^ Design: Case control study Source: SEER | First degree relative with breast cancer: none: 1 (1; 1) (OR)
Weiss, 199^64^ Design: Case control study Source: SEER | First degree relative with breast cancer: at least one vs. none: 2.5 (1.5; 4.2) (OR)
Stacey, 2008^87^ Design: Case-control study Source: Iceland, Sweden, Holland, Spain, U.S. | Single nucleotide polymorphisms: rs4415084 vs. no: 1.25 (1.05; 1.49) (OR)
Stacey, 2008^87^ Design: Case-control study Source: Iceland, Sweden, Holland, Spain, U.S. | Single nucleotide polymorphisms: rs10941679 vs. none: 1.31 (1.09; 1.59) (OR)
Stacey, 2008^87^ Design: Case-control study Source: Iceland, Sweden, Holland, Spain, U.S. | Single nucleotide polymorphisms: rs1219648 vs. no: 1.05 (0.88; 1.25) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history none (reference group): 1 (1; 1) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family historyfFirst degree vs. breast cancer family history none: 1.62 (1.26; 2.09) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history mother vs. breast cancer family history none: 1.25 (0.92; 1.7) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history sister vs. breast cancer family history none: 2.5 (1.67; 3.74) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history daughter vs. breast cancer family history none: 0.65 (0.16; 2.65) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history mother and sister vs. breast cancer family history none: 2.44 (0.83; 7.16) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history second degree vs. breast cancer family history none: 1.26 (0.99; 1.6) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history maternal grandmother vs. breast cancer family history none: 1.17 (0.72; 1.88) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history paternal grandmother vs. breast cancer family history none: 0.74 (0.39; 1.4) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history maternal aunt vs. breast cancer family history none: 1.7 (1.2; 2.42) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history paternal aunt vs. breast cancer family history none: 1.27 (0.88; 1.83) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Ovarian cancer family history None (ref): 1 (1;1) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Ovarian cancer family history first degree vs. ovarian cancer family history None: 1.32 (0.71; 2.46) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Ovarian cancer family history mother vs. ovarian cancer family history none: 1.24 (0.59; 2.61) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Ovarian cancer family history sister vs. ovarian cancer family history none: 1.51 (0.5; 4.58) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Ovarian cancer family history daughter vs. ovarian cancer family history none: N.A. (N.A.; N.A.) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Ovarian cancer family history mother and sister vs. ovarian cancer family history none: N.A. (N.A.; N.A.) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Ovarian cancer family history second degree vs. ovarian cancer family history None: 1.09 (0.56; 2.12) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Ovarian cancer family history maternal grandmother vs. ovarian cancer family history none: 0.61 (0.16; 2.35) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Ovarian cancer family history paternal grandmother vs. ovarian cancer family history None: N.A. (N.A.; N.A.) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Ovarian cancer family history maternal aunt vs. ovarian cancer family history none: 2.58 (0.73; 9.04) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Ovarian cancer family history paternal aunt vs. ovarian cancer family history none: 1.11 (0.37; 3.36) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast and ovarian family history first degree vs. none: 1.51 (0.4; 5.65) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast and ovarian family history second degree vs. none: 0.61 (0.15; 2.4) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast and ovarian family history any combination vs. none: 1.11 (0.51; 2.43) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history first degree and relative age ≤ 49 vs. none: 1.88 (1.2;2. 94) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history mother and relative age ≤ 49 vs. none: 1.31 (0.66; 2.61) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history sister degree and relative age ≤ 49 vs. none: 2.66 (1.44; 4.92) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history first degree and relative age >49 vs. none: 1.52 (1.14; 2.04) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history mother and relative age >49 vs. none: 1.24 (0.89; 1.72) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history mother and relative age >50 vs. none: 2.4 (1.43; 4.01) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history first degree and bilateral vs. none: 2.08 (1.05; 4.09) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history mother and bilateral vs. none: 1.8 (0.76; 4.23) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history sister degree and Bilateral vs. none: 2.07 (0.67; 6.36) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history first degree and unilateral vs. none: 1.56 (1.2; 2.04) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history mother and unilateral vs. none: 1.19 (0.86; 1.64) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history sister degree and unilateral vs. none: 2.56 (1.67; 3.92) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history any vs. none: 1.64 (1.15; 2.34) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history first degree vs. none: 2.12 (1.34; 3.4) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history ≤49 vs. none: 2.54 (1.28; 5.05) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history >49 vs. none: 1.85 (1.01; 3.39) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history mother vs. none: 1.72 (1.02; 2.9) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history Sister vs. none: 3.74 (1.5;9.35) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history mother and sister vs. none: 4.16 (0.43; 40.3) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history second degree vs. none: 1.18 (0.79; 1.74) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history none (reference group): 1 (1;1) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Ovarian cancer family history first degree vs. ovarian cancer family history none: 1.34 (0.4; 4.49) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Ovarian cancer family history second degree vs. ovarian cancer family history none: 1.37 (0.56; 3.38) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast and ovarian family history first degree vs. none: 1.34 (0.08; 22) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast and ovarian family history second degree vs. none: 1.29 (0.21;8.12) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast and ovarian family history any combination vs. none: 1.73 (0.42; 7.19) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history any vs. none: 1.5 (1.16; 1.92) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history first degree vs. none: 1.46 (1.08; 1.97) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history ≤49 vs. none: 1.82 (1.03; 3.21) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history >49 vs. none: 1.36 (0.98; 1.9) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history mother vs. none: 1.02 (0.7; 1.48) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history sister vs. none: 2.24 (1.44; 3.48) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history mother and sister vs. none: 1.9 (0.55; 6.54) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history second degree vs. none: 1.31 (0.97; 1.78) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast cancer family history none (reference group): 1 (1; 1) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Ovarian cancer family history First degree vs. Ovarian cancer family history None: 1.24 (0.6;2.54) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Ovarian cancer family history second degree vs. ovarian cancer family history none: 0.94 (0.37; 2.44) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast and ovarian family history first degree vs. none: 1.45 (0.32;6.51) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast and ovarian family history Second degree vs. none: 0.27 (0.03; 2.4) (OR)
Claus, 2003^75^ Design: Case control study Source: Cancer center Registry (CT) | Breast and ovarian family history any combination vs. none: 0.97 (0.39; 2.42) (OR)
Thomas S. Frank, 2002^73^ Design: Retrospective cohort Source: Genetic Laboratories (UT) | DCIS <50 years of age in Non-Ashkenazi individuals with vs. without mutations in BRCA1 and BRCA2: 0.69 (0.46; 1.06) (OR)
Trentham-Dietz, 2000^70^ Design: Case control study Source: Cancer Registry (WI) | Family history of breast cancer no (reference group): 1 (N/A; N/A) (OR)
Trentham-Dietz, 2000^70^ Design: Case control study Source: Cancer Registry (WI) | Family history of breast cancer yes vs. no: 2.68 (1.93; 3.72) (OR)
Granström, 2008^88^ Design: Prospective cohort study Source: Second Generation Swedish Family Register renamed to Multigeneration Register linked to the Swedish Cancer Registry (1958–2004) to make the Family-Cancer Database (MigMed2) | Family history of breast cancer mother vs. no history: 1.71 (1.49; 1.97) (RR)
| Family history of breast cancer sister vs. no history: 1.56 (1.28;1.9)(RR)
| No family history (reference group): 1(1:1) (RR)

Table F15 Association between blood levels of lipids, proteins, sex hormones, and mitogenes with DCIS

Study | Comparison Categories: Estimate (95% CI)
| Blood lipids
Elkhadrawy, 1998^67^ Design: Case control study Source: Cancer Center Registry (NY) | Serum cholesterol > vs. <200mg/dL: 1.66 (1.07; 2.58) (OR)
Elkhadrawy, 1998^67^ Design: Case control study Source: Cancer Center Registry (NY) | Serum cholesterol > vs. <200mg/dL: 1.15 (0.71; 1.87) (OR)
Elkhadrawy, 1998^67^ Design: Case control study Source: Cancer Center Registry (NY) | Serum cholesterol >236 vs. 72–166mg/dL: 1.89 (0.88; 4.08) (OR)
Elkhadrawy, 1998^67^ Design: Case control study Source: Cancer Center Registry (NY) | Serum cholesterol 167–207 vs. 72–166mg/dL: 1.83 (0.86; 3.88) (OR)
Elkhadrawy, 1998^67^ Design: Case control study Source: Cancer Center Registry (NY) | Serum cholesterol 208–235 vs. 72–166mg/dL: 1.1 (0.49; 2.48) (OR)
| Blood proteins
Elkhadrawy, 1998^67^ Design: Case control study Source: Cancer Center Registry (NY) | Serum albumin: 3.16 (1.82; 5.51) (OR)
Elkhadrawy, 1998^67^ Design: Case control study Source: Cancer Center Registry (NY) | Serum albumin >4.7 vs. 1.7–3.11: 9.2 (3.24; 26.14) (OR)
Elkhadrawy, 1998^67^ Design: Case control study Source: Cancer Center Registry (NY) | Serum albumin 4.4–4.6 vs. 1.7–3.10: 9.52 (3.57; 25.4) (OR)
Elkhadrawy, 1998^67^ Design: Case control study Source: Cancer Center Registry (NY) | Serum albumin 4–4.3 vs. 1.7–3.9: 4.4 (1.63; 11.85) (OR)
| Sex hormones
Zeleniuch-Jacquotte, 2005^80^ Design: Nested (New York University Women’s Health Study) Case control study Source: Women’s Health Study (NY) | DHEAS 1: 1 (1; 1) (OR)
Zeleniuch-Jacquotte, 2005^80^ Design: Nested (New York University Women’s Health Study) Case control study Source: Women’s Health Study (NY) | DHEAS 2: 0.8 (0.34; 1.87) (OR)
Zeleniuch-Jacquotte, 2005^80^ Design: Nested (New York University Women’s Health Study) Case control study Source: Women’s Health Study (NY) | DHEAS 3: 0.84 (0.35; 2.03) (OR)
Zeleniuch-Jacquotte, 2005^80^ Design: Nested (New York University Women’s Health Study) Case control study Source: Women’s Health Study (NY) | Androstenedione 1: 1 (1; 1) (OR)
Zeleniuch-Jacquotte, 2005^80^ Design: Nested (New York University Women’s Health Study) Case control study Source: Women’s Health Study (NY) | Androstenedione 2: 1.79 (0.8; 3.99) (OR)
Zeleniuch-Jacquotte, 2005^80^ Design: Nested (New York University Women’s Health Study) Case control study Source: Women’s Health Study (NY) | Androstenedione 3: 0.94 (0.41; 2.14) (OR)
Zeleniuch-Jacquotte, 2005^80^ Design: Nested (New York University Women’s Health Study) Case control study Source: Women’s Health Study (NY) | Estradiol 1: 1 (N/A; N/A) (OR)
Zeleniuch-Jacquotte, 2005^80^ Design: Nested (New York University Women’s Health Study) Case control study Source: Women’s Health Study (NY) | Estradiol 2: 1.17 (0.53; 2.57) (OR)
Zeleniuch-Jacquotte, 2005^80^ Design: Nested (New York University Women’s Health Study) Case control study Source: Women’s Health Study (NY) | Estradiol 3: 0.94 (0.4; 2.23) (OR)
Zeleniuch-Jacquotte, 2005^80^ Design: Nested (New York University Women’s Health Study) Case control study Source: Women’s Health Study (NY) | Estrone 1: 1 (N/A; N/A) (OR)
Zeleniuch-Jacquotte, 2005^80^ Design: Nested (New York University Women’s Health Study) Case control study Source: Women’s Health Study (NY) | Estrone 2: 1.83 (0.79; 4.23) (OR)
Zeleniuch-Jacquotte, 2005^80^ Design: Nested (New York University Women’s Health Study) Case control study Source: Women’s Health Study (NY) | Estrone 3: 1.02 (0.42; 2.48) (OR)
Zeleniuch-Jacquotte, 2005^80^ Design: Nested (New York University Women’s Health Study) Case control study Source: Women’s Health Study (NY) | SHBG 1: 1 (1; 1) (OR)
Zeleniuch-Jacquotte, 2005^80^ Design: Nested (New York University Women’s Health Study) Case control study Source: Women’s Health Study (NY) | SHBG 2: 0.89 (0.41; 1.91) (OR)
Zeleniuch-Jacquotte, 2005^80^ Design: Nested (New York University Women’s Health Study) Case control study Source: Women’s Health Study (NY) | SHBG 3: 1.01 (0.45; 2.3) (OR)
Zeleniuch-Jacquotte, 2005^80^ Design: Nested (New York University Women’s Health Study) Case control study Source: Women’s Health Study (NY) | Testosterone 1: 1 (1; 1) (OR)
Zeleniuch-Jacquotte, 2005^80^ Design: Nested (New York University Women’s Health Study) Case control study Source: Women’s Health Study (NY) | Testosterone 2: 1.01 (0.43; 2.38) (OR)
Zeleniuch-Jacquotte, 2005^80^ Design: Nested (New York University Women’s Health Study) Case control study Source: Women’s Health Study (NY) | Testosterone 3: 1.14 (0.44; 2.94) (OR)
| Mitogenes
Bohlke, 1998^68^ Design: Case control study Source: Cancer Registry (MA) | High risk: women with IGF-I values in the upper two control-defined tertiles and IGFBP-3 values in the lowest control-defined tertile: 3.7 (1.1; 12.2) (OR)
Bohlke, 1998^68^ Design: Case control study Source: Cancer Registry (MA) | IGFBP-3 (ng/ml) >3,493.4 vs. <3,239.4: 0.7 (0.3; 1.7) (OR)
Bohlke, 1998^68^ Design: Case control study Source: Cancer Registry (MA) | IGFBP-3 (ng/ml) <3,239.4 (reference group): 1 (1; 1) (OR)
Bohlke, 1998^68^ Design: Case control study Source: Cancer Registry (MA) | IGFBP-3 (ng/ml) 3,239.5–3,493.4 vs. <3,239.4: 0.4 (0.2; 1) (OR)
Bohlke, 1998^68^ Design: Case control study Source: Cancer Registry (MA) | IGF-I (ng/ml): >175.5 vs. <121.5: 1.8 (0.7; 4.6) (OR)
Bohlke, 1998^68^ Design: Case control study Source: Cancer Registry (MA) | IGF-I (ng/ml): <121.5 (reference group): 1 (1; 1) (OR)
Bohlke, 1998^68^ Design: Case control study Source: Cancer Registry (MA) | IGF-I (ng/ml): 121.6–175.5 vs. <121.5: 2.4 (1; 5.6) (OR)
Bohlke, 1998^68^ Design: Case control study Source: Cancer Registry (MA) | IGF-I/IGFBP-3 ratio second vs. first tertile: 1.8 (0.8; 4.2) (OR)
Bohlke, 1998^68^ Design: Case control study Source: Cancer Registry (MA) | IGF-I/IGFBP-3 ratio third vs. first tertile: 1.6 (0.7; 3.8) (OR)
Bohlke, 1998^68^ Design: Case control study Source: Cancer Registry (MA) | Intermediate risk: all other women: 1.8 (0.6; 5.3) (OR)
Bohlke, 1998^68^ Design: Case control study Source: Cancer Registry (MA) | Low risk: women with IGF-I values in the lowest tertile and IGFBP-3 values in the upper two tertiles: 1 (1; 1) (OR)

Table F16 Association between breast condition and DCIS

Study | Comparison Groups: Estimate (95% CI)
| Previous breast surgery among 30–49 years old
Kerlikowskec, 1997^65^ Design: Cross-sectional Source: Screening Program (CA) | Previous breast surgery: 1 (0.4; 2.4) (OR)
| Previous breast surgery among >50 years old
Kerlikowskec, 1997^65^ Design: Cross-sectional Source: Screening Program (CA) | Previous breast surgery: 0.9 (0.4; 1.9) (OR)
| Previous breast biopsy
Claus, 2001^71^ Design: Case control study Source: Cancer Center Registry (CT) | No Previous breast biopsy (reference group): 1 (1; 1) (OR)
Claus, 2001^71^ Design: Case control study Source: Cancer Center Registry (CT) | Previous breast biopsy: yes vs. no: 3.56 (2.86; 4.43) (OR)
Weiss, 1996^64^ Design: Case control study Source: SEER | No Previous breast biopsy (reference group): 1 (1; 1) (OR)
Weiss, 1996^64^ Design: Case control study Source: SEER | Previous breast biopsy: yes vs. no: 1.86 (1.1; 3.2) (OR)
| Premenopausal women
MacKenzie, 2007^58^ Design: Prospective cohort study Source: Screening Program (NH) | Fatty vs. scattered: 0.29 (0.04; 2.24) (RR)
MacKenzie, 2007^58^ Design: Prospective cohort study Source: Screening Program (NH) | Scattered density (reference group): 1 (1; 1) (RR)
MacKenzie, 2007^58^ Design: Prospective cohort study Source: Screening Program (NH) | Heterogeneous vs. scattered: 2.06 (1.39; 3.05) (RR)
MacKenzie, 2007^58^ Design: Prospective cohort study Source: Screening Program (NH) | Extreme vs. scattered: 2.4 (1.47; 3.91) (RR)
| Postmenopausal women
MacKenzie, 2007^58^ Design: Prospective cohort study Source: Screening Program (NH) | Fatty vs. scattered: 0.58 (0.37; 0.93) (RR)
MacKenzie, 2007^58^ Design: Prospective cohort study Source: Screening Program (NH) | Scattered density (reference group): 1 (1; 1) (RR)
MacKenzie, 2007^58^ Design: Prospective cohort study Source: Screening Program (NH) | Heterogeneous vs. scattered: 1.41 (1.12; 1.78) (RR)
MacKenzie, 2007^58^ Design: Prospective cohort study Source: Screening Program (NH) | Extreme vs. scattered: 1.49 (0.93; 2.37) (RR)
| Benign breast disease
Trentham-Dietz, 2000^70^ Design: Case control study Source: Cancer Registry (WI) | No Benign breast disease (reference group): 1 (N/A; N/A) (OR)
Trentham-Dietz, 2000^70^ Design: Case control study Source: Cancer Registry (WI) | Benign breast disease: 1.88 (1.32; 2.68) (OR)

Table F17 Association between behavioral risk factors and DCIS

Study | Comparison Groups: Estimate (95% CI)
| Diet: Alcohol intake
Gapstur, 1999^69^ Design: Prospective cohort study Source: IWHS | >4g/d: vs. 0: 0.86 (0.57; 1.29) (RR)
Gapstur, 1999^69^ Design: Prospective cohort study Source: IWHS | <4g/d: vs. 0: 1.19 (0.84; 1.69) (RR)
Trentham-Dietz, 2000^70^ Design: Case control study Source: Cancer Registry (WI) | <39 (g/week) vs. none: 1.31 (0.84; 2.05) (OR)
Trentham-Dietz, 2000^70^ Design: Case control study Source: Cancer Registry (WI) | 39–90 (g/week) vs. none: 1.68 (1.01; 2.79) (OR) ≥91(g/week) vs. none: 1.82 (1.07; 3.08) (OR)
Claus, 2001^71^ Design: Case control study Source: Cancer center Registry (CT) | Ever drink: Yes vs. no: 0.98 (0.78; 1.23) (OR)
| Diet: Daily beta-carotene intake
Trentham-Dietz, 2000^70^ Design: Case control study Source: Cancer Registry (WI) | Quartile 4 (>258 kIU) vs.1 (<760 kIU): 0.54 (0.35; 0.84) (OR)
Trentham-Dietz, 2000^70^ Design: Case control study Source: Cancer Registry (WI) | Quartile 2 (760–149 kIU) vs.1 (<760 kIU): 1.03 (0.71; 1.48) (OR)
Trentham-Dietz, 2000^70^ Design: Case control study Source: Cancer Registry (WI) | Quartile 3 (150–258 kIU) vs.1 (<760 kIU): 1.13 (0.79; 1.61) (OR)
| Average hours/week of exercise activity (10 years before reference date), no family history
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | Activity only at other ages vs. no activity, at any age: 0.62 (0.39; 0.99) (OR)
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | <1 hour/week vs. no activity, at any age: 0.7 (0.44; 1.13) (OR)
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | 1–4 hours/week vs. no activity, at any age: 0.61 (0.42; 0.9) (OR)
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | >4 hours/week vs. no activity, at any age: 0.43 (0.26; 0.69) (OR)
| Average hours/week of exercise activity 10 years after menarche
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | Activity only at other ages vs. no activity, at any age: 0.72 (0.5; 1.05) (OR)
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | <1 hour/week vs. no activity, at any age: 0.55 (0.35; 0.89) (OR)
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | 1–4 hours/week vs. no activity, at any age: 0.71 (0.48; 1.06) (OR)
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | >4 hours/week vs. no activity, at any age: 0.58 (0.36; 0.91) (OR)
| Average hours/week of exercise activity 10 years before reference date
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | Activity only at other ages vs. no activity, at any age: 0.68 (0.44; 1.06) (OR)
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | <1 hour/week vs. no activity, at any age: 0.75 (0.48; 1.16) (OR)
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | 1–4 hours/week vs. no activity, at any age: 0.61 (0.43; 0.87) (OR)
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | >4 hours/week vs. no activity, at any age: 0.52 (0.33;0.8) (OR)
| Average hours/week of exercise activity age 20–34
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | Activity only at other ages vs. no activity, at any age: 0.69 (0.47; 1) (OR)
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | <1 hour/week vs. no activity, at any age: 0.69 (0.45; 1.06) (OR)
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | 1–4 hours/week vs. no activity, at any age: 0.59 (0.39; 0.88) (OR)
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | >4 hours/week vs. no activity, at any age: 0.63 (0.36; 1.11) (OR)
| Average hours/week of exercise activity (10 years after menarche), no family history
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | Activity only at other ages vs. no activity, at any age: 0.72 (0.48; 1.07) (OR)
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | <1 hour/week vs. no activity, at any age: 0.46 (0.28; 0.77) (OR)
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | 1–4 hours/week vs. no activity, at any age: 0.69 (0.45; 1.06) (OR)
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | >4 hours/week vs. no activity, at any age: 0.48 (0.29; 0.78) (OR)
| Average hours/week of lifetime exercise activity
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | <1 hour/week vs. none: 0.66 (0.46; 0.94) (OR)
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | 1–4 hours/week vs. none: 0.66 (0.46; 0.94) (OR)
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | >4 hours/week vs. none: 0.64 (0.42; 0.96) (OR)
| Average hours/week of lifetime exercise activity, no family history
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | <1 hour/week vs. none: 0.66 (0.45; 0.97) (OR)
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | 1–4 hours/week vs. none: 0.6 (0.41; 0.88) (OR)
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | >4 hours/week vs. none: 0.53 (0.34; 0.82) (OR)
| Average MET hours/week of lifetime exercise activity
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | >0–3.0 vs. none: 0.7 (0.48; 1.03) (OR)
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | >3.0–8.0 vs. none: 0.65 (0.44; 0.96) (OR)
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | >8.0–16.0 vs. none: 0.61 (0.41; .92) (OR)
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | >16.0–32.0 vs. none: 0.63 (0.4; 0.98) (OR)
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | >32.0 vs. none: 0.65 (0.39; 1.08) (OR)
| Ever exercise activity
Patel, 2003^78^ Design: Case control study Source: SEER +WCRES | Yes vs. no: 0.65 (0.48; 0.9) (OR)
| Smoking
Claus, 2001^71^ Design: Case control study Source: Cancer center Registry (CT) | Ever smoke: Yes vs. no: 1.01 (0.82; 1.26) (OR)

Table F18 Association between nonsteroidal anti-inflammatory agents and DCIS

Study | Comparison Categories: Estimate (95% CI)
Johnson Year: 2007^74^ Design: Prospective cohort study Source: IWHS | Aspirin nonuse (reference group): 1 (1; 1) (RR) Aspirin <1/week vs. nonuse: 0.57 (0.35; 0.94) (RR) Aspirin 1/week vs. nonuse: 1.22 (0.61; 2.44) (RR) Aspirin 2–5/week vs. nonuse: 0.52 (0.28; 0.95) (RR) Aspirin 6+/week vs. nonuse: 0.52 (0.3; 0.9) (RR) NSAID use: nonuse (reference group): 1 (1; 1) (RR) NSAID use: <1 per week vs. nonuse: 1.35 (0.83; 2.21) (RR) NSAID use: 2–5 per week vs. nonuse: 0.67 (0.29; 1.56) (RR) NSAID use: 6+ per week vs. nonuse: 1.28 (0.77; 2.13) (RR)

Table F19 Cumulative crude incidence (%) of DCIS among women in the United States

Study | DCIS | Years of Events, Cumulative Incidence, %
Kreger, 1991^7^ Year of the study: 1948–1986 Data source: Framingham Heart Study | Methods to diagnose DCIS: N/S Inclusion age: 30–62 DCIS cases: 2 | Years of events: 1948–1986 Cumulative incidence in 1948–1986: 0.07%
Evans, 1997^18^ Year of the study: 1989–1995 Data source: Susan G. Komen Breast Center at Baylor University Medical Center | Methods to diagnose DCIS: Mammography Inclusion age: All ages DCIS cases: 462 | Years of events: 1989–1996 Cumulative incidence from January 1, 1989 to December 31, 1995: 12.40%
Lewis, 1975^2^ Year of the study: N/S Data source: Medical College of Wisconsin, Milwaukee | Methods to diagnose DCIS: Screening, which included a physical examination by trained technologists, thermography and xeromammography Inclusion age: N/S DCIS cases: 8 | Years of events: 1975 Cumulative incidence for first 4,500 women who were screened in 1975: 0.18%
Schwartz, 1976^3^ Year of the study: 1973–1975 Data source: Breast Diagnostic Center at Jefferson Medical College | Methods to diagnose DCIS: Clinical examination, xeroradiography, thermography Inclusion age: All ages DCIS cases: 6 | Years of events: 1973–1975 Cumulative incidence over 18 months: 0.04%
Feig, 1977^4^ Year of the study: Unknown Data source: Breast Diagnostic Center, Thomas Jefferson University Hospital in Philadelphia, Pennsylvania | Methods to diagnose DCIS: Clinical exam, mammography Inclusion age: 45–64 DCIS cases: 14 | Years of events: N/S Cumulative incidence (time of the studies was not given): 0.09%
Patchefsky, 1977^5^ Year of the study: 1973–1976 Data source: Thomas Jefferson University Hospital | Methods to diagnose DCIS: Mammography, thermography, and physical examination Inclusion age: 45–64 DCIS cases: 13 | Years of events: 1973–1976 Cumulative incidence from December 1973 through June 30, 1976: 0.07%
Curpen, 1995^12^ Year of the study: 1985–1994 Data source: Mobile van screening program | Methods to diagnose DCIS: Mammogram Inclusion age: 40–64 DCIS cases: 57 | Years of events: 1985–1994 Cumulative incidence from April 1985 to June 1994: 0.46%
MacKenzie, 2007^58^ Year of the study: 1994–2001 Data source: New Hampshire mammography registry | Methods to diagnose DCIS: Mammography Inclusion age: ≥40 DCIS cases: 265 | Years of events: 1996–2000 Cumulative incidence from June 1996 to July 2000: 0.35%
MacKenzie, 2007^58^ Year of the study: 1996–2000 Data source: Vermont mammography registry | Methods to diagnose DCIS: Mammography Inclusion age: ≥40 DCIS cases: 307 | Years of events: 1994–2001 Cumulative incidence from January 1994 to December 2001: 0.37%
Gill, 2006^51^ Year of the study: 1993–2000 Data source: Hawaii component of the Multiethnic Cohort | Methods to diagnose DCIS: Mammogram Inclusion age: All ages DCIS cases: 119 | Years of events: 1993–1996 Cumulative incidence from the time between cohort entry and December 2000: 0.10%
Kerlikowske, 2007^59^ Year of the study: 1993–2003 Data source: Breast Cancer Surveillance Consortium: San Francisco Mammography Registry, Group Health's Breast Cancer Surveillance, Colorado Mammography Advocacy Project, Vermont Breast Cancer Surveillance System, New Hampshire Mammography Network, Carolina Mammography Registry, New Mexico, Mammography Registry | Methods to diagnose DCIS: Mammography Inclusion age: ≥30 DCIS cases: 550 | Years of events: 1993–2003 Cumulative incidence from January 1993 to December 2003: 0.18%
Ernster, 2002^30^ Year of the study: 1996–1997 Data source: Breast Cancer Surveillance Consortium mammography registries located in Colorado, New Hampshire, New Mexico, North Carolina, San Francisco (CA), Vermont and western Washington State | Methods to diagnose DCIS: Mammography Inclusion age: 40–84 DCIS cases: 591 | Years of events: 1996–1998 Cumulative incidence among screening mammography examinations from January 1996 to December 1997: 0.09%
Nekhlyudov, 2006^49^ Year of the study: 1992–2000, Data source: The Department of Ambulatory Care and Prevention, | Methods to diagnose DCIS: mammography Inclusion age: Not specified DCIS cases: 510 | Years of events: 1992–2000 Incidence per 100,000 person-years for 8 years of the study: 5556.60%
Weaver, 2006^52^ Year of the study: 1996–2001 Data source: Breast Cancer Surveillance Consortium - only the 5 registries that collect both pathology data and cancer registry data were included | Methods to diagnose DCIS: Mammogram Inclusion age: 40–89 DCIS cases: 1672 | Years of events: 1996–2001 Cumulative incidence from 1996–2001: 0.10%
Kerlikowske, 2005^47^ Year of the study: 1986–2001 Data source: San Francisco Mammography Registry | Methods to diagnose DCIS: Mammography Inclusion age: ≥40 DCIS cases: 493 | Years of events: 1986–2001 Cumulative incidence from January 1986 to December 2001: 0.48%

Table F20 Cumulative incidence of DCIS per 1,000 mammograms among U.S. females

Study | DCIS, Control for Bias | Patient Subpopulations and Cumulative Incidence per 1,000 Mammograms (95% CI)
Kerlikowske, 2005^47^ Year of the study: 1986–2001 Data source: San Francisco Mammography Registry | DCIS cases: 2 Inclusion age: ≥40 Adjustment: Adjusted for age, previous mammogram, family history of breast cancer, age at live birth, and BMI | Years of the events: 1986–2001 Race: Non-Hispanic white Age: All Cumulative incidence per 1,000 mammograms from January 1986 to December 2001: 1.7 (1.5; 1.9)
Kerlikowske, 2005^47^ Year of the study: 1986–2001 Data source: San Francisco Mammography Registry | DCIS cases: 2 Inclusion age: ≥40 Adjustment: Adjusted for age, previous mammogram, family history of breast cancer, age at live birth, and BMI | Years of the events: 1986–2001 Race: Chinese Age: All Cumulative incidence per 1,000 mammograms from January 1986 to December 2001: 1.6 (1.3; 2.1)
Kerlikowske, 2005^47^ Year of the study: 1986–2001 Data source: San Francisco Mammography Registry | DCIS cases: 2 Inclusion age: ≥40 Adjustment: Adjusted for age, previous mammogram, family history of breast cancer, age at live birth, and BMI | Years of the events: 1986–2001 Race: Filipino Age: All Cumulative incidence per 1,000 mammograms from January 1986 to December 2001: 1.7 (1.3; 2.5)
Kerlikowske, 2000^27^ Year of the study: April 1985 - November Data source: Mammography registries in nine states | DCIS cases: 6 Inclusion age: 30–39 Adjustment: Adjusted for family history of breast cancer and age | Years of the events: 1985–1997 Race: All Age: 30–39 Cumulative incidence from April 1985 to November 1997 per 1,000 mammograms: 1 (N/A; N/A)
Kerlikowske, 2000^27^ Year of the study: April 1985 - November Data source: Mammography registries in nine states | DCIS cases: 19 Inclusion age: 30–39 Adjustment: Adjusted for family history of breast cancer and age | Years of the events: 1985–1997 Race: All Age: 30–39 Cumulative incidence from April 1985 to November 1997 per 1,000 mammograms: 0.5 (N/A; N/A)
Kerlikowske, 2000^27^ Year of the study: April 1985 - November Data source: Mammography registries in nine states | DCIS cases: 24 Inclusion age: 40–49 Adjustment: Adjusted for family history of breast cancer and age | Years of the events: 1985–1997 Race: All Age: 40–49 Cumulative incidence from April 1985 to November 1997 per 1,000 mammograms: 1.211 (N/A; N/A)
Kerlikowske, 2000^27^ Year of the study: April 1985 - November Data source: Mammography registries in nine states | DCIS cases: 106 Inclusion age: 40–49 Adjustment: Adjusted for family history of breast cancer and age | Years of the events: 1985–1997 Race: All Age: 40–49 Cumulative incidence from April 1985 to November 1997 per 1,000 mammograms: 0.776 (N/A; N/A)
Kerlikowske, 2000^27^ Year of the study: April 1985 - November Data source: Mammography registries in nine states | DCIS cases: 17 Inclusion age: 50–59 Adjustment: Adjusted for family history of breast cancer and age | Years of the events: 1985–1997 Race: All Age: 50–59 Cumulative incidence from April 1985 to November 1997 per 1,000 mammograms: 1.24 (N/A; N/A)
Kerlikowske, 2000^27^ Year of the study: April 1985 - November Data source: Mammography registries in nine states | DCIS cases: 102 Inclusion age: 50–59 Adjustment: Adjusted for family history of breast cancer and age | Years of the events: 1985–1997 Race: All Age: 50–59 Cumulative incidence from April 1985 to November 1997 per 1,000 mammograms 1.05 (N/A; N/A)
Kerlikowske, 2000^27^ Year of the study: April 1985 - November Data source: Mammography registries in nine states | DCIS cases: 23 Inclusion age: 60–69 Adjustment: Adjusted for family history of breast cancer and age | Years of the events: 1985–1997 Race: All Age: 60–69 Cumulative incidence from April 1985 to November 1997 per 1000 mammograms: 2.042 (N/A; N/A)
Kerlikowske, 2000^27^ Year of the study: April 1985 - November Data source: Mammography registries in nine states | DCIS cases: 88 Inclusion age: 60–69 Adjustment: Adjusted for family history of breast cancer and age | Years of the events: 1985–1997 Race: All Age: 60–69 Cumulative incidence from April 1985 to November 1997 per 1,000 mammograms: 1.31 (N/A; N/A)
Smith-Bindman, 2005^45^ Year of the study: 1996–1999 Data source: Breast Cancer Surveillance Consortium with mammography registries in San Francisco (California), Colorado, New Hampshire, New Mexico, North Carolina, Western Washington and Vermont | DCIS cases: 2 Inclusion age: ≥50 Adjustment: Adjusted by setting and screening cycle | Years of the events: First screening mammogram, 1996–1999 Race: All Age: All Cumulative incidence over 3 years per 1,000 screening mammograms adjusted by setting and screening cycle: 1.5 (1.2; 1.8)
| DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted by setting and screening cycle | Years of the events: Subsequent screening mammogram, 1996–1999 Race: All Age: All Cumulative incidence over 3 years per 1,000 screening mammograms adjusted by setting and screening cycle: 0.83 (0.77; 0.9)
Kerlikowske, 2007^57^ Year of the study: 1997–2004 Data source: 4 Breast Cancer Surveillance Consortium mammography registries: San Francisco Mammography Registry, Group Health’s Breast Cancer Surveillance Project, Vermont Breast Cancer Surveillance System, and New Hampshire Mammography Network | DCIS cases: 1 Inclusion age: 50–69 Adjustment: Crude | Years of the events: 1997 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1997 to December 2003: 0.9 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 50–69 Adjustment: Crude | Years of the events: 1998 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1997 to December 2003: 1 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 50–69 Adjustment: Crude | Years of the events: 1999 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1997 to December 2003: 1.2 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 50–69 Adjustment: Crude | Years of the events: 2000 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1997 to December 2003: 1.5 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 50–69 Adjustment: Crude | Years of the events: 2001 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1997 to December 2003: 1.3 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 50–69 Adjustment: Crude | Years of the events: 2002 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1997 to December 2003: 1.3 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 50–69 Adjustment: Crude | Years of the events: 2003 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1997 to December 2003: 1.2 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 50–69 Adjustment: Crude | Years of the events: 2004 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1997 to December 2003: 1.7 (N/A; N/A)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: Breast Cancer Surveillance Consortium consisting of mammography registries from San Francisco, California; Colorado; New Hampshire; New Mexico; North Carolina; Seattle, Washington; Vermont | DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 50–54 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 1.3 (0.7; 2.1)
| DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 55–59 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 0.63 (0.2; 1.6)
| DCIS cases: 2 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 60–64 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 2.4 (1.2; 4.1)
| DCIS cases: 2 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: ≥65 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 2 (1.3; 3.1)
| DCIS cases: 2 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: All Cumulative incidence age-adjusted to a standard age distribution per 1,000 screening mammograms from January 1996 to December 1999: 1.5 (1.2; 1.8)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: National Breast and Cervical Cancer Early Detection Program | DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 50–54 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 1.3 (0.9; 1.7)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: National Breast and Cervical Cancer Early Detection Program | DCIS cases: 2 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 55–59 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 2.1 (1.4; 2.7)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: National Breast and Cervical Cancer Early Detection Program | DCIS cases: 3 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 60–64 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 3 (2.1; 3.8)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: National Breast and Cervical Cancer Early Detection Program | DCIS cases: 2 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: ≥65 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 1.7 (0.6; 2.8)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: National Breast and Cervical Cancer Early Detection Program | DCIS cases: 2 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: All Cumulative incidence age-adjusted to a standard age distribution per 1,000 screening mammograms from January 1996 to December 1999: 1.9 (1.7; 2.2)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: Breast Cancer Surveillance Consortium consisting of mammography registries from San Francisco, California; Colorado; New Hampshire; New Mexico; North Carolina; Seattle, Washington; Vermont | DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 50–54 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 0.77 (0.6; 0.9)
| DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 55–59 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 0.73 (0.6; 0.9)
| DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 60–64 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 0.96 (0.8; 1.2)
| DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: ≥65 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 1 (0.9; 1.2)
| DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: All Cumulative incidence age-adjusted to a standard age distribution per 1,000 screening mammograms from January 1996 to December 1999: 0.83 (0.77; 0.9)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: National Breast and Cervical Cancer Early Detection Program | DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 50–54 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 1.1 (0.86; 1.3)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: National Breast and Cervical Cancer Early Detection Program | DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 55–59 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 1.1 (0.83; 1.3)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: National Breast and Cervical Cancer Early Detection Program | DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 60–64 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 1.2 (0.93; 1.5)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: National Breast and Cervical Cancer Early Detection Program | DCIS cases: 2 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: ≥65 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 1.6 (1; 2.1)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: National Breast and Cervical Cancer Early Detection Program | DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: All Cumulative incidence age-adjusted to a standard age distribution per 1,000 screening mammograms from January 1996 to December 1999: 1.2 (1.1; 1.3)
Ernster, 2002^30^ Year of the study: 1996–1997 Data source: Breast Cancer Surveillance Consortium mammography registries located in Colorado, New Hampshire, New Mexico, North Carolina, San Francisco (CA), Vermont and western Washington state | DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 40–49 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.54 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 50–59 Cumulative incidence per 1,000 mammograms from January 1996 to December 1998: 0.74 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 60–69 Cumulative incidence per 1,000 mammograms from January 1996 to December 1999: 1 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 70–84 Cumulative incidence per 1,000 mammograms from January 1996 to December 2000: 1.31 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1996 to December 2001: 0.81 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 40–49 Cumulative incidence per 1,000 mammograms from January 1996 to December 2002: 0.57 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 50–59 Cumulative incidence per 1,000 mammograms from January 1996 to December 2003: 0.66 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 60–69 Cumulative incidence per 1,000 mammograms from January 1996 to December 2004: 1.04 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 70–84 Cumulative incidence per 1,000 mammograms from January 1996 to December 2005: 0.97 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1996 to December 2006: 0.76 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 40–49 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.56 (0.41;0.7)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 50–59 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.68 (0.52; 0.85)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 60–69 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 1.03 (0.83; 1.23)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 70–84 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 1.07 (0.87; 1.27)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.78 (0.6; 0.95)
| DCIS cases: 0 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 40–49 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.08 (0.02; 0.13)
| DCIS cases: 0 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 50–59 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.09 (0.03; 0.15)
| DCIS cases: 0 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 60–69 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.19 (0.11; 0.28)
| DCIS cases: 0 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 70–84 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.22 (0.13; 0.31)
| DCIS cases: 0 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.13 (0.05; 0.2)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 40–49 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.63 (0.48; 0.79)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 50–59 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.77 (0.6; 0.95)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 60–69 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 1.22 (1; 1.44)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 70–84 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 1.28 (1.06; 1.51)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.9 (0.72; 1.09)

Table F21 Cumulative incidence of DCIS per 1,000 mammograms among U.S. females

Study | DCIS, Control for Bias | Patient Subpopulations and Cumulative Incidence per 1,000 Mammograms (95% CI)
Kerlikowske, 2005^47^ Year of the study: 1986–2001 Data source: San Francisco Mammography Registry | DCIS cases: 2 Inclusion age: ≥40 Adjustment: Adjusted for age, previous mammogram, family history of breast cancer, age at live birth, and BMI | Years of the events: 1986–2001 Race: Non-Hispanic white Age: All Cumulative incidence per 1,000 mammograms from January 1986 to December 2001: 1.7 (1.5; 1.9)
Kerlikowske, 2005^47^ Year of the study: 1986–2001 Data source: San Francisco Mammography Registry | DCIS cases: 2 Inclusion age: ≥40 Adjustment: Adjusted for age, previous mammogram, family history of breast cancer, age at live birth, and BMI | Years of the events: 1986–2001 Race: Chinese Age: All Cumulative incidence per 1,000 mammograms from January 1986 to December 2001: 1.6 (1.3; 2.1)
Kerlikowske, 2005^47^ Year of the study: 1986–2001 Data source: San Francisco Mammography Registry | DCIS cases: 2 Inclusion age: ≥40 Adjustment: Adjusted for age, previous mammogram, family history of breast cancer, age at live birth, and BMI | Years of the events: 1986–2001 Race: Filipino Age: All Cumulative incidence per 1,000 mammograms from January 1986 to December 2001: 1.7 (1.3; 2.5)
Kerlikowske, 2000^27^ Year of the study: April 1985 - November Data source: Mammography registries in nine states | DCIS cases: 6 Inclusion age: 30–39 Adjustment: Adjusted for family history of breast cancer and age | Years of the events: 1985–1997 Race: All Age: 30–39 Cumulative incidence from April 1985 to November 1997 per 1,000 mammograms: 1 (N/A; N/A)
Kerlikowske, 2000^27^ Year of the study: April 1985 - November Data source: Mammography registries in nine states | DCIS cases: 19 Inclusion age: 30–39 Adjustment: Adjusted for family history of breast cancer and age | Years of the events: 1985–1997 Race: All Age: 30–39 Cumulative incidence from April 1985 to November 1997 per 1,000 mammograms: 0.5 (N/A; N/A)
Kerlikowske, 2000^27^ Year of the study: April 1985 - November Data source: Mammography registries in nine states | DCIS cases: 24 Inclusion age: 40–49 Adjustment: Adjusted for family history of breast cancer and age | Years of the events: 1985–1997 Race: All Age: 40–49 Cumulative incidence from April 1985 to November 1997 per 1,000 mammograms: 1.211 (N/A; N/A)
Kerlikowske, 2000^27^ Year of the study: April 1985 - November Data source: Mammography registries in nine states | DCIS cases: 106 Inclusion age: 40–49 Adjustment: Adjusted for family history of breast cancer and age | Years of the events: 1985–1997 Race: All Age: 40–49 Cumulative incidence from April 1985 to November 1997 per 1,000 mammograms: 0.776 (N/A; N/A)
Kerlikowske, 2000^27^ Year of the study: April 1985 - November Data source: Mammography registries in nine states | DCIS cases: 17 Inclusion age: 50–59 Adjustment: Adjusted for family history of breast cancer and age | Years of the events: 1985–1997 Race: All Age: 50–59 Cumulative incidence from April 1985 to November 1997 per 1,000 mammograms: 1.24 (N/A; N/A)
Kerlikowske, 2000^27^ Year of the study: April 1985 - November Data source: Mammography registries in nine states | DCIS cases: 102 Inclusion age: 50–59 Adjustment: Adjusted for family history of breast cancer and age | Years of the events: 1985–1997 Race: All Age: 50–59 Cumulative incidence from April 1985 to November 1997 per 1,000 mammograms 1.05 (N/A; N/A)
Kerlikowske, 2000^27^ Year of the study: April 1985 - November Data source: Mammography registries in nine states | DCIS cases: 23 Inclusion age: 60–69 Adjustment: Adjusted for family history of breast cancer and age | Years of the events: 1985–1997 Race: All Age: 60–69 Cumulative incidence from April 1985 to November 1997 per 1000 mammograms: 2.042 (N/A; N/A)
Kerlikowske, 2000^27^ Year of the study: April 1985 - November Data source: Mammography registries in nine states | DCIS cases: 88 Inclusion age: 60–69 Adjustment: Adjusted for family history of breast cancer and age | Years of the events: 1985–1997 Race: All Age: 60–69 Cumulative incidence from April 1985 to November 1997 per 1,000 mammograms: 1.31 (N/A; N/A)
Smith-Bindman, 2005^45^ Year of the study: 1996–1999 Data source: Breast Cancer Surveillance Consortium with mammography registries in San Francisco (California), Colorado, New Hampshire, New Mexico, North Carolina, Western Washington and Vermont | DCIS cases: 2 Inclusion age: ≥50 Adjustment: Adjusted by setting and screening cycle | Years of the events: First screening mammogram, 1996–1999 Race: All Age: All Cumulative incidence over 3 years per 1,000 screening mammograms adjusted by setting and screening cycle: 1.5 (1.2; 1.8)
| DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted by setting and screening cycle | Years of the events: Subsequent screening mammogram, 1996–1999 Race: All Age: All Cumulative incidence over 3 years per 1,000 screening mammograms adjusted by setting and screening cycle: 0.83 (0.77; 0.9)
Kerlikowske, 2007^57^ Year of the study: 1997–2004 Data source: 4 Breast Cancer Surveillance Consortium mammography registries: San Francisco Mammography Registry, Group Health’s Breast Cancer Surveillance Project, Vermont Breast Cancer Surveillance System, and New Hampshire Mammography Network | DCIS cases: 1 Inclusion age: 50–69 Adjustment: Crude | Years of the events: 1997 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1997 to December 2003: 0.9 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 50–69 Adjustment: Crude | Years of the events: 1998 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1997 to December 2003: 1 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 50–69 Adjustment: Crude | Years of the events: 1999 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1997 to December 2003: 1.2 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 50–69 Adjustment: Crude | Years of the events: 2000 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1997 to December 2003: 1.5 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 50–69 Adjustment: Crude | Years of the events: 2001 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1997 to December 2003: 1.3 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 50–69 Adjustment: Crude | Years of the events: 2002 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1997 to December 2003: 1.3 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 50–69 Adjustment: Crude | Years of the events: 2003 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1997 to December 2003: 1.2 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 50–69 Adjustment: Crude | Years of the events: 2004 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1997 to December 2003: 1.7 (N/A; N/A)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: Breast Cancer Surveillance Consortium consisting of mammography registries from San Francisco, California; Colorado; New Hampshire; New Mexico; North Carolina; Seattle, Washington; Vermont | DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 50–54 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 1.3 (0.7; 2.1)
| DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 55–59 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 0.63 (0.2; 1.6)
| DCIS cases: 2 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 60–64 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 2.4 (1.2; 4.1)
| DCIS cases: 2 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: ≥65 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 2 (1.3; 3.1)
| DCIS cases: 2 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: All Cumulative incidence age-adjusted to a standard age distribution per 1,000 screening mammograms from January 1996 to December 1999: 1.5 (1.2; 1.8)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: National Breast and Cervical Cancer Early Detection Program | DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 50–54 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 1.3 (0.9; 1.7)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: National Breast and Cervical Cancer Early Detection Program | DCIS cases: 2 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 55–59 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 2.1 (1.4; 2.7)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: National Breast and Cervical Cancer Early Detection Program | DCIS cases: 3 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 60–64 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 3 (2.1; 3.8)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: National Breast and Cervical Cancer Early Detection Program | DCIS cases: 2 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: ≥65 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 1.7 (0.6; 2.8)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: National Breast and Cervical Cancer Early Detection Program | DCIS cases: 2 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: All Cumulative incidence age-adjusted to a standard age distribution per 1,000 screening mammograms from January 1996 to December 1999: 1.9 (1.7; 2.2)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: Breast Cancer Surveillance Consortium consisting of mammography registries from San Francisco, California; Colorado; New Hampshire; New Mexico; North Carolina; Seattle, Washington; Vermont | DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 50–54 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 0.77 (0.6; 0.9)
| DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 55–59 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 0.73 (0.6; 0.9)
| DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 60–64 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 0.96 (0.8; 1.2)
| DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: ≥65 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 1 (0.9; 1.2)
| DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: All Cumulative incidence age-adjusted to a standard age distribution per 1,000 screening mammograms from January 1996 to December 1999: 0.83 (0.77; 0.9)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: National Breast and Cervical Cancer Early Detection Program | DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 50–54 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 1.1 (0.86; 1.3)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: National Breast and Cervical Cancer Early Detection Program | DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 55–59 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 1.1 (0.83; 1.3)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: National Breast and Cervical Cancer Early Detection Program | DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: 60–64 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 1.2 (0.93; 1.5)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: National Breast and Cervical Cancer Early Detection Program | DCIS cases: 2 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: ≥65 Cumulative incidence per 1,000 screening mammograms from January 1996 to December 1999: 1.6 (1; 2.1)
Smith-Bindman, 2003^32^ Year of the study: 1996–1999 Data source: National Breast and Cervical Cancer Early Detection Program | DCIS cases: 1 Inclusion age: ≥50 Adjustment: Adjusted to a standard age distribution | Years of the events: 1996–1999 Race: All Age: All Cumulative incidence age-adjusted to a standard age distribution per 1,000 screening mammograms from January 1996 to December 1999: 1.2 (1.1; 1.3)
Ernster, 2002^30^ Year of the study: 1996–1997 Data source: Breast Cancer Surveillance Consortium mammography registries located in Colorado, New Hampshire, New Mexico, North Carolina, San Francisco (CA), Vermont and western Washington state | DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 40–49 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.54 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 50–59 Cumulative incidence per 1,000 mammograms from January 1996 to December 1998: 0.74 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 60–69 Cumulative incidence per 1,000 mammograms from January 1996 to December 1999: 1 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 70–84 Cumulative incidence per 1,000 mammograms from January 1996 to December 2000: 1.31 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1996 to December 2001: 0.81 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 40–49 Cumulative incidence per 1,000 mammograms from January 1996 to December 2002: 0.57 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 50–59 Cumulative incidence per 1,000 mammograms from January 1996 to December 2003: 0.66 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 60–69 Cumulative incidence per 1,000 mammograms from January 1996 to December 2004: 1.04 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 70–84 Cumulative incidence per 1,000 mammograms from January 1996 to December 2005: 0.97 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1996 to December 2006: 0.76 (N/A; N/A)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 40–49 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.56 (0.41;0.7)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 50–59 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.68 (0.52; 0.85)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 60–69 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 1.03 (0.83; 1.23)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 70–84 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 1.07 (0.87; 1.27)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.78 (0.6; 0.95)
| DCIS cases: 0 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 40–49 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.08 (0.02; 0.13)
| DCIS cases: 0 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 50–59 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.09 (0.03; 0.15)
| DCIS cases: 0 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 60–69 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.19 (0.11; 0.28)
| DCIS cases: 0 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 70–84 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.22 (0.13; 0.31)
| DCIS cases: 0 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.13 (0.05; 0.2)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 40–49 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.63 (0.48; 0.79)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 50–59 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.77 (0.6; 0.95)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 60–69 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 1.22 (1; 1.44)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: 70–84 Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 1.28 (1.06; 1.51)
| DCIS cases: 1 Inclusion age: 40–84 Adjustment: Crude | Years of the events: 1996–1998 Race: All Age: All Cumulative incidence per 1,000 mammograms from January 1996 to December 1997: 0.9 (0.72; 1.09)

Table F22 BRCA-associated DCIS detected with MIR screening in prospective case-series (modified from Hagen, 2007)99

Author | Country | Population | Age | N | Followup | DCIS | % DCIS | Low 95% CI | Upper 95% CI
Kuhl, 2000^100^ | Germany | High risk women including mutation carriers | 39 (18–65) | 192 | 1 year | 0 | 0.3 | 0 | 4
Warner, 2001^101^ | Canada | High risk women including mutation carriers | 43 (26–59) | 196 | | 0 | 0.3 | 0 | 3.9
Podo, 2002^102^ | Italy | High risk women including mutation carriers | 46 (25–77) | 105 | | 1 | 1 | 0.1 | 6.4
Kriege, 2004^103^ | The Netherlands | High risk women including mutation carriers | 40 (19–72) | 1,909 | 2.9 years | 1 | 0.1 | 0 | 0.4
Warner, 2004^104^ | Canada | Mutation carriers | 47 (26–65) | 236 | | 0 | 0.2 | 0 | 3.3
Leach, 2005^41^ | UK | High risk women including mutation carriers | 40 (31–55) | 649 | | 1 | 0.2 | 0 | 1.1
Hagen, 2007^99^ | Norway | BRCA1/2 mutation carriers | 41 (18–79) | 491 | 0.5 years | 3 | 0.6 | 0.2 | 1.9
Hartman, 2004^105^ | USA | BRCA1 or BRCA2 mutations or women with a >10% risk of developing breast carcinoma at 10 years, as estimated by the Claus model | 42.5 (27– 72) | 41 | | 1 | 2.4 | 0.3 | 15.4

Table F23 The role of MRI in DCIS

Study / Sampling / Patients | Outcome
Chung, 2005^106^ Design: Case-series Evidence: III Sample: 28 MRI: MRI studies were performed with the patient prone in a 1.5 T magnet (Quantum; Siermens. Erlangen, Germany) using a dedicated surface breast coil and bilateral scans were obtained after intravenous injection of 0.1 mmol per kilogram of body weight of gadodiainidc (Oinnipaque: Aniersham. Princeton. NJ) Source: Saul and Joyce Brandman Breast Center, Cedars-Sinai Medical Center, Los Angeles, California Inclusion: Retrospective review of these 54 patients with DCIS constituting at least 50 per cent of their disease who underwent breast MRI from January 2003 to November 2004 in Saul and Joyce Brandman Breast Center Exclusion: NR DCIS: DCIS was diagnosed as “abnormality on mammogram“ (25 patients), 23 presented with either a palpable mass or bloody nipple discharge on clinical exam; 5 patients had lesions that were detected by MRI screening; 1 patient presented with DCIS discovered incidentally on pathology examination of a breast reduction specimen Patients: In patients with pure DCIS (28), 10 of the tumors were <1 cm in size. 8 patients had lesions estimated between 1 and 3 cm in size, and 10 patients were found to have tumors greater than 3 cm (8 of which were extensive, multifocal lesions). Age: 52; Range: 38–73 | Treatment The plan of care before MRI was local excision (either lumpectomy or reexcision). Change in management based on MRI findings: 7/28 (25%)
| Biopsy Ipsilateral cancer Additional biopsies performed for ipsilateral lesions were performed in 2 patients who had lesions detected by MRI directed ultrasound. They underwent biopsies localized by ultrasound and were found to have DCIS. Contralateral biopsies were performed in 2 (7%) patients for lesions detected by MRI. One patient had a lesion that was positive for DCIS while one was negative for malignancy.
| Contralateral biopsy Contralateral cancer Contralateral biopsies were performed in 2 patients for lesions detected by MRI. One patient had a lesion that was positive for DCIS while one was negative for malignancy
| Diagnosis DCIS 6 false-negative cases, 5 of which were found to be positive for DCIS at the margins of the biopsy cavity
Solin, 2008^107^ Design: Case-series Evidence: III Sample: 136 MRI: MRI methodology as previously described Source: The Hospital of the University of Pennsylvania (Philadelphia, PA) Inclusion: Women who underwent breast-conservation treatment including definitive breast irradiation for stage 0 breast cancer (American Joint Commission on Cancer) at the Hospital of the University of Pennsylvania (Philadelphia, PA) from 1992 to 2001. Exclusion: NR DCIS: DCIS, no details on methods of diagnosis Patients: NR among DCIS Age: NR; Range: NR | Local failure 136 patients with DCIS, the 8-year rate of any local failure was 6% vs. 6% with or without MRI, respectively: the use of breast MRI was not associated with an improvement in outcomes after BCT with radiation
Hwang, 2003^108^ Design: Case-series Evidence: III Sample: 51 MRI: MRI was performed on a Signa system (GE Medical Systems, Milwaukee, WI) in a prone position in a dedicated double breast coil after injection of .1 mmol/kg of gadolinium diethylenetriamine pentaacetic acid (Magnevist; Berlex Laboratories Inc., Wayne, NJ). Source: Department of Surgery, University of California-San Francisco, San Francisco Inclusion: Patients with histologically confirmed diagnosis of DCIS alone at the time of MRI examination undergoing surgical treatment from 1996 to 1999 in Department of Surgery, University of California-San Francisco, San Francisco Exclusion: NR DCIS: DCIS alone histologically confirmed. Diagnostic criteria for DCIS in MRI were (1) nonstippled regional or segmental enhancement or (2) irregular ductal enhancement. Before MRI, the diagnosis of DCIS was obtained by core biopsy in 17 and by open surgical biopsy in 34 patients. Patients: Abnormal mammogram 37; Palpable mass 9; Nipple discharge 5; Mode of diagnosis: Core biopsy 17; Surgical biopsy 34; Tumor grade: Low 9; Intermediate 11;High 19 Age: NR; Range: NR | Residual disease Sensitivity: 97% Specificity: 58%
| Invasive disease Sensitivity: 86% Specificity: 82%
| Multicentricity Sensitivity: 94% Specificity: 89%
| Residual disease, differences between mammography (MMG) and magnetic resonance imaging (MRI) Sensitivity -17% (p<0.05) Specificity -15% Accuracy -15% PPV -2% NPV -54% (p<0.05)
| Occult invasion, differences between mammography (MMG) and magnetic resonance imaging (MRI) Sensitivity -71%(p<0.05) Specificity 15%(p<0.05) Accuracy -1% PPV 7% NPV -14% (p<0.05)
| Multicentricity, differences between mammography (MMG) and magnetic resonance imaging (MRI) Sensitivity -58%(p<0.05) Specificity 1% Accuracy -24%(p<0.05) PPV -6% NPV -29% (p<0.05)
Tillman, 2002^109^ Design: Case-series Evidence: III Sample: 41 MRI: MRI was performed on a Signa system (GE Medical Systems, Milwaukee, WI) with a 1.5-Tesla magnet in the prone position using dedicated multicoil array system (two coils on each of two plates) and contrast enhancement with 20 mL of gadopentetate dimeglumine (Magnevist; Berlex Laboratories, Wayne, NJ). MRI for performed after a mammogram suggestive of disease, but before any tissue diagnosis; after a core biopsy or fine-needle aspiration, but before excisional biopsy; after an excisional biopsy that resulted in positive or close surgical margins, but before re-excisional biopsy; after an excisional biopsy, with no re-excision performed; or after a re-excisional biopsy. Source: The Hospital of the University of Pennsylvania Inclusion: Records review of consecutive series of patients with DCIS who underwent breast MRI from November 1992 through June 2000 during breast conservation treatment at the Hospital of the University of Pennsylvania. Inclusion criteria: diagnosis of ductal carcinoma-in-situ (DCIS; intraductal carcinoma), American Joint Committee on Cancer (AJCC) clinical stage 0, (Tis N0 M0) in patients with difficult management decisions; breast MRI studies performed at the Hospital of the University of Pennsylvania; definitive local treatment of mastectomy or breast conservation treatment performed at the Hospital of the University of Pennsylvania. Exclusion: Breast lesion not diagnosed as breast cancer; direct mastectomy without consultation by radiation oncology for consideration of breast conservation treatment; MRI studies after neoadjuvant chemotherapy or after breast irradiation; local recurrence after breast conservation treatment; axillary lymphadenopathy for presumed occult primary breast carcinoma with negative mammogram findings; lobular carcinoma-in-situ or Paget’s disease of the nipple (AJCC stage Tis N0 M0); locally advanced disease at presentation (AJCC stage T3-4 and/or N2-3). DCIS: DCIS with no further details Patients: no details reported Age: 50; Range: 23–79 | Definition of the outcome: An extent of which MRI findings caused any change in the patient’s local management. No effect: MRI simply confirmed information already obtained by mammogram, ultrasound, or clinical examination; MRI findings were discordant with other information, but were not acted on. MRI did not affect clinical management: 35/41- 85.4% Definition of the outcome: An extent of which MRI findings caused any change in the patient’s local management. MRI affected clinical management: 6/41 - 14.6% Definition of the outcome: An extent of which MRI findings caused any change in the patient’s local management. Strongly favorable on the basis of the MRI findings: (1) the MRI findings prompted or hastened a biopsy that otherwise would not have been performed, and for which the additional excised tissue was positive for cancer; (2) the MRI findings prompted or hastened a mastectomy that revealed the presence of significant residual disease in the breast (eg, extensive microscopic disease, gross multifocal disease, or gross multicentric disease) that would not have been removed by excisional biopsy or re-excision; or (3) The MRI findings prompted the surgeon to widen the excision or excise an additional area at the time of excision, with the resultant pathology revealing cancer in the additional resected tissue. Somewhat favorable: (1) the MRI served as an aid before surgery in localizing the tumor in three dimensions because of mammographic limitations (eg, lesion visible only on a single mammographic view or prior unsuccessful mammographic needle localization procedure performed); or (2) the MRI findings were diagnostically benign such that a biopsy was spared for a lesion that would otherwise have required a biopsy. Effect of MRI favorable:5 / 41- 12.2% Definition of the outcome: An extent of which MRI findings caused any change in the patient’s local management. Uncertain: Mastectomy was prompted or hastened by the MRI findings, and the disease found on pathology might or might not have been managed equally well by breast conservation treatment on the basis of the size or location of disease. Effect of MRI uncertain: 0/41 -0.0% Definition of the outcome: An extent of which MRI findings caused any change in the patient’s local management. Somewhat unfavorable effect: Patients who had a negative biopsy based on a false-positive MRI finding, but who were still able to conserve their breasts. These women underwent an extra surgical procedure of a negative breast biopsy, but ultimately underwent breast conservation treatment. Strongly unfavorable: Patients for whom a mastectomy was performed on the basis of the MRI findings, and for whom the mastectomy pathology findings were minimal or no residual disease, and therefore, these patients could have been managed by breast conservation treatment. Effect of MRI unfavorable: 1 in 4 DCIS - 2.4% Type of Surgery MRI-Prompted and MRI-Hastened Biopsy: 3 Type of Surgery MRI-Prompted and MRI-Hastened Mastectomy: 4
Bluemke, 2004^110^ Design: Multicenter study Evidence: IIB Sample: 63 MRI: High resolution 3-dimensional MRI of the breast at 1.5 T using a dedicated breast coil followed by a 3- dimensional T1-weighted set of images taken immediately prior to and after the intravenous administration of 0.1 mmol/kg of gadolinium chelate. Patients with focal abnormalities on 3-dimensional MRI were asked to return for a dynamic MRI with an additional injection of gadolinium contrast (2-dimensional, T1-weighted images centered on the focal abnormality were acquired at 15- second intervals after the administration of 0.1 mmol/kg of gadolinium chelate administered over 10 seconds). Source: The International Breast Magnetic Resonance Consortium study Inclusion: Prospective multicenter investigation of the International Breast MR Consortium conducted at 14 university hospitals in North America and Europe from June 2, 1998, through October 31, 2001, of women 18 to 80 years old who were referred for breast biopsy because a mammogram (2 months of the MRI examination) was classified as American College of Radiology (ACR) category 4 or 5 (suspicious abnormality, highly suggestive of malignancy, respectively) or if the patient had a suspicious clinical or ultrasound finding without associated benign mammographic features. Exclusion: Prior excisional or core biopsy of the affected breast was performed less than 6 months before enrollment, contraindication to MRI (eg, pacemaker, ferromagnetic DCIS: DCIS diagnosed using core needle biopsies and excision specimens Patients: Not reported Age: Not reported; Range: Not reported | MRI sensitivity to diagnose DCIS Tumor 1–5mm: 0/4 - 0% Tumor 6–10mm 9/10c 90% (55.5–99.7) Tumor 11–15mm 11/14c 78.6% (49.2–95.3) Tumor 16–20 6/8c 75% (34.9–96.8) Tumor >21 13/18 72.2% (46.5–90.3) Sensitivity, % (95% CI) 73% (60.3–83.4) Specificity, % (95% CI) 67.4% (62.7–71.9) PPV, % (95% CI) 25.3% (19.1–32.2) NPV, % (95% CI) 94.3 (91.0–96.6) AUC (95% CI) 0.76 (0.68–0.83)
Kuhl, 2007^111^ Design: Case-series Evidence: III Sample: 165 MRI: MRI was performed using 1.5T system (Intera and Intera Achieva, Philips Medical Systems, Best, Netherlands) with a dedicated bilateral multielement breast surface coil (four-channel Breast Array Coil, In Vivo and Philips Medical Systems, Best, Netherlands). The imaging protocol consists of a T2-weighted axial turbo spin echo pulse sequence without fat suppression, followed by the dynamic contrast enhanced series after bolus injection of 0•1 mmol/kg bodyweight gadopentetate dimeglumine (Magnevist, Bayer Schering Healthcare, Berlin, Germany) Source: Academic tertiary care breast centre at the University of Bonn Hospital and Medical School. Inclusion: Women with a family history of breast cancer and a calculated lifetime risk of 20% or more, as based on geneticist’s assessment, and women in followup after breast conserving treatment who had MRI between January 2, 2002, and December 31, 2006, due to non- normal screening mammogram, normal conventional imaging studies, but clinical symptoms of breast cancer, normal conventional imaging studies, but at an increased risk for (primary or recurrent) breast cancer, normal conventional imaging and an average risk, but were concerned about breast cancer and wished to undergo MRI as an additional screening test. Exclusion: MRI without mammography DCIS: Final surgical diagnosis of pure DCIS (without associated invasive breast cancer or micro-invasion) independent of their detestability on imaging studies Patients: 165 women had an imaging diagnosis of BI- RADS 4 or 5 and received the final pathological diagnosis of pure DCIS.97 (58%) had an average risk for breast cancer and had been referred for regular screening; 44 (26%) were in followup after breast cancer, 14 (8%) underwent screening for familial breast cancer, and 12 (7%) had clinical symptoms (nipple discharge in six, palpable lump in three, nipple retraction in two, and Paget’s disease in one) Age: 54.1; Range: 31–84 | Diagnosis of DCIS Sensitivity of MRI for DCIS detection
| All DCIS (n=167) 153 – 92% (86–95%)
| All non-high-grade DCIS (n=78) 66 – 85% (74–91%) Low grade (n=44) 35 – 80% (64–90%) Intermediate grade (n=34) 31 – 91% (75–98%)
| All high-grade DCIS (n=89) 87 – 98% (91–100%) High grade, with necroses (n=55) 54 – 98% (89–99%) High grade, without necroses (n=34) 33 – 97% (83–100%)
| Sensitivity of MRI and mammography by nuclear grading Low grade 15 – 34% Intermediate grade 14 – 41% High grade 43 – 48%
| Diagnosis of DCIS Only MRI positive DCIS (mammography false negative) 72 – (100%)
| Diagnosis of DCIS Low grade - 15 (21%) All non-high grade - 29 (40%) High grade - 43 (60%)
| Diagnosis of DCIS Present- 29 (40%) Absent - 43 (60%) Diagnosis of DCIS by Oestrogen-receptor status Not available - 7 (10%) Diagnosis of DCIS Positive - 48 (67%) Diagnosis of DCIS Negative - 17 (24%)
| Diagnosis of DCIS Progesterone-receptor status Not available - 7 (10%) Positive - 44 (61%) Negative- 21 (29%)
| Size Range 4–70 Mean (SD) 26·4 (16·1) Median (IQR) 23·5 (14·0–35·0)
| VNPI Determined by scoring DCS size, nuclear grade, presence or absence of necroses, and margin width, with VNPI values ranging between 3 and 9. Range 3–9 Mean (SD) 5·9 (1·4) Median (IQR) 6 (5·0–7·0)
Lehman, 2007^112^ Design: Multicenter study Evidence: IIB Sample: 196 MRI: MRI was performed using 1.5-T or larger magnet, a dedicated breast-surface coil, and one image obtained before and two images obtained after the administration of contrast material, with three-dimensional, T1-weighted, gradient-echo sequences. Source: ACRIN Trial 6667 Investigators Group Inclusion: Women 18 years of age or older diagnosed with unilateral breast cancer within 60 days before the study MRI was performed and with normal clinical and mammographic findings in the contralateral breast within 90 days before enrollment in participating centers between April 1, 2003, and June 10, 2004. Exclusion: Breast MRI within 12 months before enrollment, pregnancy, contraindication for MRI, breast-cancer diagnosis made more than 60 days before enrollment, chemotherapy or hormonal therapy for breast cancer within 6 months before enrollment. DCIS: DCIS diagnosed using histologic examination of a biopsy specimen Patients: Not reported Age: Not reported; Range: Not reported | Contralateral cancer associated with a BI-RADS 1 or BI- RADS 3 score (indicating a false negative result of MRI) False negative for MRI contralateral cancer The three tumors were pure ductal carcinomas in situ and were 1, 3, and 4 mm in diameter
| DCIS detected by MRI in contrlateral breast, otherwise occult True positive detected by MRI only 12 Among 196 women with DCIS: Contrlateral cancer detected by MRI - 5 Sensitivity 71% (29–96) Specificity 90% (86–94) Negative predictive value – 99% (96–100) Positive predictive value − 21% (5–37) Fitted AUC p value 0.8; Standard error 10
Hollingsworth, 2008,^113^ Design: Case-series Evidence: III Sample: 149 MRI: MRI was performed after manual infusion of .2 mmol/kg gadolinium an Aurora (North Andover, MA, USA) breast-dedicated .5- Tesla MRI with bilateral breast coil Or with high-resolution rotating delivery of excitation off-resonance (RODEO®) axial acquisitions using an Aurora 1.5- Tesla breast-dedicated MRI Source: Department of Surgery, Mercy Health Center, Oklahoma City, OK Inclusion: March 2003 through December 2006, Consecutive patients newly diagnosed with DCIS who underwent additional surgery shortly after the MRI, providing the basis for correlating histology and MRI findings from March 2003 through December 2006 in the Department of Radiology, Mercy Health Center, Mercy Women’s Center, Oklahoma City Exclusion: Neoadjuvant chemotherapy, refused surgical intervention after the MRI, lost to followup evaluation, radiation therapy after definitive surgical excision DCIS: DCIS diagnosed using image-guided biopsy or surgical biopsy. Multicentric disease was defined as a separate focus of cancer more than 5.0 cm away from the index lesion or tumors that extended to another quadrant through a discontinuous growth pattern, the latter definition being more common with lobular histology Patients: Not reported Age: Not reported; Range: Not reported | Treatment Breast conservation 63%
| Bilateral mastectomies, mostly for prevention 19%
| Breast conservation when unilateral approach was chosen for unilateral disease 77% (91 of 118).
| Multicentric cancers detected by MRI in addition to Mammography and ultrasound Multicentric DCIS-18
| Multiquadrant high grade DCIS 9
| Multicentric cancers not detected by MRI but found in surgical biopsy False-negative rate of multicentirc DCIS (high-grade and multiquadrant) 5
| Contralateral cancers detect by MRI in addition to Mammography and ultrasound Contralateral cancer among patients with DCIS 4.70%
Menell, 2005^114^ Design: Case-series Evidence: III Sample: 32 MRI: MRI was performed with 1.5 T system (Signa, General Electric Medical Systems, Milwaukee, WI) using a dedicated breast coil (MRI Devices, Waukesha, WI). Imaging sequences included a localizing sequence followed by a sagittal fat-suppressed T2-weighted sequence after bolus injection of 0.1 mmol/L of gadopentetate dimeglumine (Magnevist, Berlex, Wayne, NJ) per kilogram of body weight. Source: Memorial Sloan-Kettering Cancer Center, New York, New York, USA. Inclusion: Retrospective review of medical records of women who underwent MRI and mammographic examination during a 23-month period due to increased risk for developing breast cancer (personal or strong family history of breast cancer, genetic predisposition to breast cancer, prior biopsy diagnosis of atypia or lobular carcinoma in situ, or prior irradiation for Hodgkin’s disease). Exclusion: Microinvasive tumor DCIS: Pure DCIS confirmed with histological examination. DCIS was considered multicentric if it was present in more than one quadrant. DCIS was considered multifocal if the distance between DCIS sites was ≥ 2 cm and was within the same quadrant Patients: 32 women with pure DCIS, 28 breasts containing one lesion, 4 breasts containing two lesions, and 1 breast containing three lesions. Indications for performing breast MRI were the extent of disease in 15, high-risk screening in 15, and problem solving in 3 Age: 53; Range: 34–79 | Diagnosis of DCIS DCIS detected by MRI only 21 (64%)
| Diagnosis of DCIS False negative for MRI DCIS 3 (9%) Of the three breasts without imaging findings for DCIS, two were in prophylactic mastectomies (one in a woman with contralateral cancer and the other with a prior biopsy yielding LCIS), and one was in a woman with a history of Paget’s disease diagnosed by nipple biopsy. The size of the DCIS lesions not identified by imaging was 0.1–0.2 cm.
| Diagnosis of DCIS Sensitivity to detect DCIS by MRI 29/33=88%
| Multicentric DCIS Multiple sites of DCIS by MRI only 3 (from 5 multicentric DCIS in histology) Of the four breasts with multiple lesions seen on MRI, three were evident as linear/ductal nonmass enhancement at all sites and one had mass enhancement at two sites and linear/ductal enhancement at a third site
| Multicentric DCIS. Multiple sites of DCIS by MRI and mammography 1 (from 5 multicentric DCIS in histology)
| Multicentric DCIS. False negative for MRI multicentric DCIS 1 (from 5 multicentric DCIS in histology)
| Multifocal DCIS detected by MRI 1 from 1 in histology
| Treatment. Change in surgical treatment to mastectomy due to MRI findings 3 (60% of 5 cases)
| Odds ratio of High grade DCIS detection by MRI vs. mammography 13.5(1.20; 152.21)
| Odds ratio of Intermediate grade DCIS detection by MRI vs. mammography 45 (4.43; 457.48)
Menell, 2005^114^ Design: Case-series Evidence: III Sample: 32 MRI: MRI was performed with 1.5 T system (Signa, General Electric Medical Systems, Milwaukee, WI) using a dedicated breast coil (MRI Devices, Waukesha, WI). Imaging sequences included a localizing sequence followed by a sagittal fat-suppressed T2-weighted sequence after bolus injection of 0.1 mmol/L of gadopentetate dimeglumine (Magnevist, Berlex, Wayne, NJ) per kilogram of body weight. Source: Memorial Sloan-Kettering Cancer Center, New York, New York, USA. Inclusion: Retrospective review of medical records of women who underwent MRI and mammographic examination during a 23-month period due to increased risk for developing breast cancer (personal or strong family history of breast cancer, genetic predisposition to breast cancer, prior biopsy diagnosis of atypia or lobular carcinoma in situ, or prior irradiation for Hodgkin’s disease). Exclusion: Microinvasive tumor DCIS: Pure DCIS confirmed with histological examination. DCIS was considered multicentric if it was present in more than one quadrant. DCIS was considered multifocal if the distance between DCIS sites was ≥2 cm and was within the same quadrant Patients: 32 women with pure DCIS, 28 breasts containing one lesion, 4 breasts containing two lesions, and 1 breast containing three lesions. Indications for performing breast MRI were the extent of disease in 15, high-risk screening in 15, and problem solving in 3s Age: 53; Range: 34–79 | Diagnosis of DCIS Odds ratio of low grade DCIS detection by MRI vs. mammography 16 (1.79; 143.15)
Brem, 2007^115^ Design: Case-series Evidence: III Sample: 20/8 had MRI MRI: MRI was performed using a GE 1.5-T system (GE Healthcare, Milwaukee, WI) using a dedicated breast Coil and initial 3-dimensional localizing sequence followed by sagittal T1-w depending on fat saturation. 3-dimensional volumetric dynamic images were obtained followed by a sagittal T1 (6.3/2.9 –12) fat-saturated postcontrast sequence after administration of 33 mL of gadopentetate-dimeglumine (Magnevist, Berlex, Germany). High- resolution breast-specific gamma imaging was performed after injection of 25–30 mCi (925–1,110 MBq) technetium 99m-sestamibi in small-field-of-view gamma camera (Dilon 6800; Dilon Technologies, Newport News, VA) Source: Breast Imaging and Intervention, The George Washington University, Washington, DC Inclusion: Retrospective review of 20 nonpregnant women, mean 55 years (range 34–76 years) diagnosed with pure DCIS after definitive biopsy or at surgical excision between July 2001 and July 2006 Exclusion: DCIS: biopsy-proven DCIS lesions Patients: 20 women with 22 biopsy-proven DCIS lesions, 2 bilateral DCIS with tumor size ranging from 2 to 21 mm (mean 9.9 mm). Four DCIS lesions were less than 5 mm in size, two 6–10 mm in size, two 11–20 mm in size, and one >20 mm in size. Nuclear grading were classified as high (n = 11), intermediate (n =9), and low (n = 2). Comedonecrosis was present in 10 DCIS, all intermediate- or high-grade tumors. Breast MRI was performed in seven patients with eight biopsy-proven foci of DCIS Age: 55; Range: 34–76 | Diagnosis of DCIS Sensitivity of MRI to detect DCIS 7/8 (88%) Occult contralateral DCIS Sensitivity of MRI to detect contralateral DCIS 1/1 (100%) Diagnosis of DCIS False negative for MRI DCIS 1 (44mm DCIS)
Uematsu, 2008 116 Design: Case-series Evidence: III Sample: 24 DCIS cases MRI: Preoperative MR with 1.5T commercially available system (Gyroscan Intera; Philips Medical Systems, Best, The Netherlands) with double breast-surface coils. The imaging protocol included alocalizing sequence followed by sagittal fast-spin echo T2-weighted imaging Source: Breast Imaging Section in Shizuoka Cancer Center Hospital, Japan Inclusion: Consecutive women with clinical, mammographic, and sonographic findings that were highly suggestive of breast cancer were recruited from January 2003 to August 2004 after consent. Exclusion: Unable to provide consent or undergo MR imaging because of a pacemaker, claustrophobia, or a nontitanium metallicclip Patients: 6 comedo DCIS, 3 comedo multifocal and 3 comedo multicentric DCIS; 18 noncomedo DCIS, 14 noncomedo multifocal and 4 noncomedo multicentric DCIS Age: 57; Range: 25–87 years | Compared to preoperative core needle biopsy, MRI missed 1 case of noncomedo DCIS. Among patients with DCIS the overall accuracy of tumor extent from MRI was 88% compared to multidetector row computed tomography 67% (p=0.063). Accuracy of tumor extent among 6 patients with comedo DCIS was 83% after MRI and 50% after multidetector row computed tomography (p=0.5). Accuracy of tumor extent among 18 patients with noncomedo DCIS was 89% for MRI vs.72% for multidetector row computed tomography (p=0.063).
| Accuracy of MRI vs. ultrasound:
| | MRI | US | P value
| DCIS | 88 | 63 | 0.031
| Comedo DCIS | 83 | 67 | 1
| Noncomedo | 89 | 61 | 0.063
| Accuracy of MRI vs. mammography
| | MRI | US | P value
| DCIS | 88 | 33 | <0.0001
| Comedo DCIS | 83 | 67 | 1
| Noncomedo | 89 | 22 | <0.0001
Houserkova, 2008^117^ Design: Case-series Evidence: III Sample: 32 DCIS cases MRI: was performed in a prone position with double breast coil using 1.5T system (Siemens Symphony, Erlangen, Germany, Siemens). Imaging included a localizer followed by transverse turbo-spin echo T2–weighted sequence Source: Department of Radiology, Palacky University, Czech Republic Inclusion: Consecutive patients with mammographically detected BI-RADS 5 microcalcifi cations and mammographically dense type of breast were recruited from January 2004 to December 2006 Exclusion: Contraindications to MRI (with claustrophobia or pacemaker) Patients: 32 women with final histology after surgery as DCIS, 22 pure DCIS and 10 DCIS with microinvasion Age: 50.5; Range: 34–72 years | Multifocality of DCIS was found by MRI in 6 (19 %) women and bilateral carcinoma in one of the patients. The sensitivity of contrast-enhanced breast MRI in assessment of BI-RADS 5 microcalcifi cation lesion was 94%, the accuracy 94%, PPV 100 % and NPV 50%.
Onesti, 2008^118^ Design: Case-series Evidence: III Sample: 16 DCIS cases MRI: was performed using1.5-T whole body MR scanner with bilateral breast coils (Siemens, Malvern, PA). T1- weighted images were acquired with the body coil through each axilla Source: Department of Surgery, The University of Kansas School of Medicine-Wichita Inclusion: Retrospective chart review of all women who had undergone a breast MRI from January 2000 through August 2007 within a breast surgery specialty practice Exclusion: Not reported Patients: 16 women with final histology after surgery as DCIS Age: Not reported among women with DCIS | Concordance between MRI and pathology was defined as a difference <0.5 cm Mean over-estimation of DCIS size by MRI vs. pathology 1.29 ±0.40cm Concordance with MRI – 8 cases (50%) Overestimated by MRI − 8 cases (50%) DCIS overestimated by MRI by greater than 0.5 cm (8 cases): Mean overestimation 2.40 ±0.57cm
Santamaria, 2008^119^ Design: Case-series Evidence: III Sample: 86 histologically proven cases of pure DCIS MRI: The first 50 patients in the study were examined using a 1-T MR system (Magnetom Impact, Siemens, Erlangen, Germany) and the more recent group of 36 patients was examined using a 1.5-T MR system (Symphony, Siemens, Erlangen, Germany). Source: Department of Radiology, Barcelona, Spain Inclusion: Retrospective review of the records of all women with pure DCIS who had MRI between March 1999 and June 2005 Patients: 86 women with intraductal carcinomas without light-microscopic signs of microinvasion or invasive cancer Age: 57 years (range, 30–90 years) | Multicentricity was diagnosed if DCIS occupied more than one quadrant of the breast. MRI showed greater sensitivity than mammography in detection of multicentricity (42% vs. 26%) although the difference between both techniques was not significant.
Pediconi, 2005^120^ Design: Case-series Evidence: III Sample: 11 DCIS cases MRI: was performed using 1.5 T magnet (Siemens, Vision Plus, Germany) Source: Department of Radiology, University of Rome, Italy Inclusion: Consecutive patients with unilateral breast cancer, with a negative contralateral breast at physical examination, ultrasound, and mammography Exclusion: Contraindications to MRI (with claustrophobia or pacemaker) Patients: 11 women with final histology of DCIS Age: Not reported among women with DCIS | MRI detected 5 cases of contralateral DCIS that were missed by mammography, 1 contralateral DCIS was diagnosed in women with a primary DCIS.
Liberman, 2003^121^ Design: Case-series Evidence: III Sample: 36 DCIS cases MRI: was performed with the patient prone in a 1.5-T commercially available system (Signa; General Electric Medical Systems, Milwaukee, WI) using a dedicated surface breast coil (Breast Array Coil for General Electric Signa System; MRI Devices, Waukesha, WI). Source: Memorial Sloan-Kettering Cancer Center, USA Inclusion: Retrospective review of records of 1,336 consecutive breast MR imaging examinations over a 2-year period with unilateral breast cancer that was diagnosed within 6 months before MR imaging; asymptomatic contralateral breast with negative mammogram of the contralateral breast obtained within 6 months of MR imaging. Exclusion: Not reported Patients: 36 women with final histology of DCIS Age: Not reported among women with DCIS | MRI detected contralateral breast cancer
| % | Lower 95% CI | Upper 95% CI
| 5.6 | 1.4 | 19.7
Schouten van der Velden,2006^122^ Design: Case-series Evidence: III Sample: 54 DCIS cases MRI: was performed 1.5 Tesla (Symphony, Siemens, Germany) with the patient placed in a prone position with the breasts hanging in a double-breast coil Source: Department of Surgical Oncology, Radboud University Nijmegen Medical Centre, the Netherlands Inclusion: Retrospective review of records of consecutive female patients with a histopathologically confirmed diagnosis of DCIS, of whom 12 showed small invasive carcinoma (<10 mm), in the period between January 1998 and February 2005. MRI studies were randomly performed and no specific criteria were used to determine whether patients underwent an MRI or not Exclusion: Not reported Patients: 54 women with final histology of DCIS, Age: Not reported among women with pure DCIS | Definition of error estimating tumor size: +/− 5mm
| Over estimation, % | 95% CI
| 38 | 26 | 52
| Under estimation, % | 95% CI
| 24 | 14.5 | 37.1

Table F24 Accuracy and surgical impact of magnetic resonance imaging in detection of multifocal and multicentric ductal carcinoma in situ (modified from systematic review and meta-analysis)1

Study | Outcome | Outcome Estimate
Houssami, 2008^1^ Country: Australia Sample: 2,610 | Additional disease (all multifocal and multicentric cancers) detected by MRI | 16%
Houssami, 2008^1^ Country: Australia Sample: 2,610 | MRI incremental accuracy to detect multifocal and multicentric cancer | 99% to 86% as the quality of reference standard
Houssami, 2008^1^ Country: Australia Sample: 2,610 | Positive predictive value | 66% (52% – 77%)
Houssami, 2008^1^ Country: Australia Sample: 2,610 | True positive: false positive ratio | 1.91 (1.09 – 3.34)
Houssami, 2008^1^ Country: Australia Sample: 2,610 | Conversion from wide local excision to mastectomy | 8.10% (5.9%–11.3%)
Houssami, 2008^1^ Country: Australia Sample: 2,610 | Conversion from wide local excision to more extensive surgery in multifocal or multicentric disease | 11.30% (6.8% –18.3%)
Hollingsworth, 2006^123^ Country: USA Sample: 85 DCIS among 1,913 BC | Breast conservation | 55/85, 64.7%
Hollingsworth, 2006^123^ Country: USA Sample: 85 DCIS among 1,913 BC | Bilateral mastectomy | 16/85, 18.8%
Hollingsworth, 2006^123^ Country: USA Sample: 85 DCIS among 1,913 BC | Unilateral mastectomy | 14/85, 16.4%
Hollingsworth, 2006^123^ Country: USA Sample: 85 DCIS among 1,913 BC | Multicentric DCIS | 10/85, 11.8%
Hollingsworth, 2006^123^ Country: USA Sample: 85 DCIS among 1,913 BC | Multicentric DCIS | 6 high grade, multi-quadrant disease in addition to index quadrant (4 patients had 3 and 4 quadrant involvement)
Hollingsworth, 2006^123^ Country: USA Sample: 85 DCIS among 1,913 BC | False negative by MRI BC when multicentric cancer was discovered in mastectomy specimen | 4: 1.5cm invasive cancer, 1.4cm high grade DCIS, 0.5cm papillary DCIS, 2-quadrant high grade DCIS with no measurement by pathology
Hollingsworth, 2006^123^ Country: USA Sample: 85 DCIS among 1,913 BC | Multicentric DCIS detected by MRI | 5/79, 6.3%
Hollingsworth, 2006^123^ Country: USA Sample: 85 DCIS among 1,913 BC | Contralateral cancer discovered by MRI | 4/85, 4.7%
Schelfout, 2004^124^ Country: Belgium Sample: 41 pure DCIS among 170 women with BC | Additional DCIS detected by MRI only | 10 additional pure DCIS foci in 33 patients
Schelfout, 2004^124^ Country: Belgium Sample: 41 pure DCIS among 170 women with BC | Grade of additional index DCIS detected by MRI only | 1 high grade DCIS
Zhang, 2002^125^ Country: Japan Sample: 12 MRI detected DCIS among 54 patients with BC | Additional DCIS cases detected by MRI only | MRI detected 4 additional to mammography DCIS and 1 additional to ultrasound DCIS

Table F25 Treatment utilization and patient outcomes in relation to sentinel node biopsy in patients with DCIS

Author, Country, Source of Data | N Positive Sentinel Nodes | Definition of the Outcome | Patients
Intra, 2008^126^ Country: Italy Source: The European Institute of Oncology | 12 | Adjuvant treatment | All 12 patients with positive SLN and 3 patients with ITC in the SLN received adjuvant treatment: endocrine therapy alone was offered to 9 patients and chemotherapy alone to 6 patients.
Intra, 2008^126^ Country: Italy Source: The European Institute of Oncology | 12 | Radiotherapy | All 11 patients who had undergone breast conservative surgery received complementary radiotherapy to the breast at the standard dose
Murphy, 2008 Murphy, 2008 #3553} Country: USA Source: Medical records in the Division of Surgical Oncology, Brigham and Women’s Hospital, Boston, MA | N/R | Recurrences were identified by chart review. Local recurrences were defined as in-breast recurrence after breast conservation, chest wall recurrence after mastectomy, or recurrence within the axilla. All other recurrences were considered distant. | Seven positive SNB patients had completion axillary lymph node dissections, and no additional positive nodes were revealed. 2 patients who underwent mastectomy received chest wall radiation, 1 for a focally positive posterior margin.
Intra, 2003^127^ Country: Italy Source: The European Institute of Oncology | 7 | Radiotherapy | All patients whose SLN was positive for metastases, except for 1 who underwent a mastectomy, underwent standard external radiotherapy (5000 rad [50 Gy] to the whole breast and 1000 rad [10 Gy] as a boost to the tumor bed. The other 216 patients whose SLNs were negative for metastases underwent external radiotherapy only in case of high-grade DCIS.
Intra, 2003^127^ Country: Italy Source: The European Institute of Oncology | 7 | Adjuvant treatment | All 7 patients whose SLNs were positive for metastases were examined for adjuvant therapy according to the main predictive and prognostic factors. Adjuvant therapy for these patients was as follows: patients 1 and 3, a combination of doxorubicin hydrochloride (Adriamycin) and cyclophosphamide for 4 cycles and a combination of cyclophosphamide, methotrexate, and fluorouracil for 3 cycles; patients 2 and 7, tamoxifen citrate; patient 4, a luteinizing hormone–releasing hormone analogue; patient 5, tamoxifen citrate and a luteinizing hormone– releasing hormone analogue; and patient 6, a combination of cyclophosphamide, methotrexate, and fluorouracil for 3 cycles and tamoxifen citrate.
Intra, 2003^127^ Country: Italy Source: The European Institute of Oncology | 7 | Complete axillary dissection during a second session | All patients with DCIS, except for 1 with a metastatic SLN, underwent a complete axillary dissection during a second session. One patient with 1 micrometastatic SLN and 3 other first-level nonmetastatic nodes, informed about the risks, refused complete axillary dissection
Huo, 2006^128^ Country: USA Source: The University of Texas M. D. Anderson Cancer Center | 3 | Axillary lymph node dissection | All 3 patients with positive SNB underwent a completion axillary lymph node dissection
Polom, 2008^129^ Country: Poland Source: 1st Department of Oncological and General Surgery, Wielkopolska Cancer Centre | 2 | Axillary lymph node dissection | All 2 patients with metastases to the sentinel node underwent axillary lymphadenectomy
Dominguez, 2008^130^ Country: USA Source: Massachusetts General Hospital and Brigham and Women s Hospital, in Boston, Massachusetts | 16 | Axillary lymph node dissection | Three patients underwent ALND on the basis of positive SNBs and in each the SNB was the only positive node. Eighteen of 19 patients with unsuspected invasive cancer were able to avoid axillary dissection on the basis of SNB results
Dominguez, 2008^130^ Country: USA Source: Massachusetts General Hospital and Brigham and Women s Hospital, in Boston, Massachusetts | 16 | Adjuvant treatment | Seven patients (37%) received adjuvant chemotherapy, including two patients found to have an ipsilateral invasive carcinoma and two patients who had a contralateral synchronous invasive breast cancer. Only two patients received chemotherapy as a result of a positive sentinel node with only DCIS identified in the breast. Twelve out of 19 patients (63%) with a positive sentinel node received hormonal therapy with tamoxifen or an aromatase inhibitor
Mabry, 2006^131^ Country: USA Source: USC/Norris Cancer Center and the Van Nuys Breast Center | 10 | Adjuvant treatment | None of the IHC-positive patients were treated with chemotherapy
Tunon-de-Lara, 2008^132^ Country: France Source: 6 French Cancer Centers (Marseille, Lille, Nantes, Rouen, Rennes, and Bordeaux) | 6 | Axillary lymph node dissection | ALND was performed in five of the six positive SN patients and none was found positive. The sixth declined recommended axillary dissection
Sakr, 2008^133^ Country: France Source: Department of Gynecology; Department of Pathology; and Department of Radiology, Hospital Tenon, Paris, France | 9 | Complete axillary lymph node dissection | 1 patient with positive SN among pure DCIS and 1 patient with positive SN among DCISM
Yen, 2005^134^ Country: USA Source: The University of Texas MD Anderson Cancer Center | 14 | Adjuvant treatment | Among patients with pure DCIS and positive SN, 1 patient was administered with tamoxifen and anastrozole, one had monotherapy with tamoxifen +chemotherapy, and one had chemotherapy. 1 patient with positive SN among DCISM was treated with anastrozole
Sakr, 2006^135^ Country: France Source: Department of Gynecology, Hopital Tenon, Paris, France | 9 | Axillary lymph node dissection | All 4 patients with positive SN among pure DCIS with pure micropapillary and high-grade DCIS, underwent complete ALND
Sakr, 2006^135^ Country: France Source: Department of Gynecology, Hopital Tenon, Paris, France | 9 | Axillary lymph node dissection | 1 patient with DCISM and positive SN had initial diffuse DCIS and underwent mastectomy with axillary lymph node exploration and second complete ALND
Katz, 2006^136^ Country: USA Source: Sibley Memorial Hospital (SMH) in Washington DC | 8 | Axillary lymph node dissection | Two of 8 patients with positive SLNs (both by H&E) underwent completion axillary dissection, and neither was found to have additional involved axillary nodes.
Katz, 2006^136^ Country: USA Source: Sibley Memorial Hospital (SMH) in Washington DC | 8 | Adjuvant treatment | None of the patients with pure DCIS received adjuvant chemotherapy
Katz, 2006^136^ Country: USA Source: Sibley Memorial Hospital (SMH) in Washington DC | 8 | Recurrence | None of 8 patients with positive SN had local, distant, or regional recurrence
Katz, 2006^136^ Country: USA Source: Sibley Memorial Hospital (SMH) in Washington DC | 8 | Axillary lymph node dissection | One of 6 patients with a positive SLN among high risk group underwent completion axillary dissection and was not found to have additional positive axillary nodes
Katz, 2006^136^ Country: USA Source: Sibley Memorial Hospital (SMH) in Washington DC | 8 | Axillary lymph node dissection | One patient with a positive SLN on H&E staining among those that had mastectomy underwent a completion axillary dissection and did not have any additional involved axillary nodes
Katz, 2006^136^ Country: USA Source: Sibley Memorial Hospital (SMH) in Washington DC | 8 | Axillary lymph node dissection | The patient with the positive SLN by H&E staining among those with DCISM had a 3-mm SLN metastasis and was found to have 1 of 10 involved additional nodes on completion axillary dissection. The other patient had a micrometastasis and did not undergo completion axillary dissection
Katz, 2006^136^ Country: USA Source: Sibley Memorial Hospital (SMH) in Washington DC | 8 | Adjuvant treatment | The patient with microinvasive breast cancer, a 3-mm SLN metastasis, and an additional node on completion axillary dissection received adjuvant chemotherapy.
Katz, 2006^136^ Country: USA Source: Sibley Memorial Hospital (SMH) in Washington DC | 8 | Recurrence | None of 2 patients with DCISM and positive SN experienced a local, regional, or distant recurrence of breast cancer
Klauber-DeMore, 2000^137^ Country: USA Source: Memorial Sloan-Kettering Cancer Center | 3 | Axillary lymph node dissection | Six of nine patients with DCIS and three of three with DCISM and positive sentinel nodes had completion axillary dissection; one patient with DCIS had an additional positive node detected by conventional histological analysis
Tan, 2007^138^ Country: Canada Source: the University of Toronto Health Network database | 7 | Axillary lymph node dissection | Among 5 patients with pure DCIS and positive SNB, 2 patients with icrometastases (pN1mi) and underwent axillary lymph node dissection
Tan, 2007^138^ Country: Canada Source: the University of Toronto Health Network database | 7 | Adjuvant treatment | From 4 patients with pure DCIS and positive SNB, one underwent chemotherapy
Tan, 2007^138^ Country: Canada Source: the University of Toronto Health Network database | 7 | Radiation | From 4 patients with pure DCIS and positive SNB one underwent radiation
Moore, 2007^139^ Country: USA Source: John Wayne Cancer Institute (JWCI), Memorial Sloan-Kettering Cancer Center (MSKCC), and the University of Southern California (USC), | 43 | Adjuvant treatment | 27 from 43 patients with positive SNB received systemic treatment: 9 received chemotherapy alone, 11 received hormone therapy alone, and 7 received chemotherapy and hormonal therapy
Moore, 2007^139^ Country: USA Source: John Wayne Cancer Institute (JWCI), Memorial Sloan-Kettering Cancer Center (MSKCC), and the University of Southern California (USC), | 43 | Death from hepatic metastases | 1 patient with positive SNB, high-grade DCIS with necrosis, microinvasion, treated with mastectomy and immediate tissue transfer reconstruction and adjuvant tamoxifen
Veronesi, 2005^140^ Country: Italy Source: the European Institute of Oncology in Milan | 9 | Loco-regional r systemic events | No events were observed in the nine SLN-positive patients.
Veronesi, 2005^140^ Country: Italy Source: the European Institute of Oncology in Milan | 9 | Axillary lymph node dissection | Eight from none patients with positive SNB underwent complete axillary dissection
Mittendorf, 2005^141^ Country: USA Source: the Comprehensive Breast Center at Walter Reed Army Medical Center | 9 | Axillary lymph node dissection | Completion axillary dissection was performed in 2 patients with pure DICS and positive SNB at the discretion of the attending surgeon, and no additional positive lymph nodes were identified
Mittendorf, 2005^141^ Country: USA Source: the Comprehensive Breast Center at Walter Reed Army Medical Center | 9 | Adjuvant treatment | One patient with a sentinel lymph node that was positive for micrometastatic disease by IHC only underwent chemotherapy despite no evidence of invasive disease found in her primary lesion
Gray, 2007^142^ Country: USA Source: the Mayo Clinic in Arizona and the cancer registries of the Mayo Clinic sites in Arizona, Jacksonville, and Rochester | 6 | Local, regional, and distant disease | All patients were alive and free of local, regional, and distant disease
van la Parra, 2008^143^ Country: The Netherlands Source: Department of Surgery, Jeroen Bosch Ziekenhuis, The Netherlands | 5 | Axillary lymph node dissection | All 5 patients with positive SNB underwent axillary dissection. No additional positive axillary lymph nodes were found
van la Parra, 2008^143^ Country: The Netherlands Source: Department of Surgery, Jeroen Bosch Ziekenhuis, The Netherlands | 5 | Local recurrences or systemic metastases | No local recurrences and no systemic metastases
Camp, 2005^144^ Country: USA Source: Departments of Surgery and Pathology, University of Florida | 7 | Axillary lymph node dissection | Four of the seven patients with positive SLNs underwent an axillary dissection and none of these patients was found to have any non-SLN metastases
Zavagno, 2007^145^ Country: Italy Source: 6 academic centers in Italy | 4 | Axillary lymph node dissection | All four patients with positive SLN underwent complete ALND and in all these cases further metastatic axillary nodes were found
Intra, 2003^146^ Country: Italy Source: Prospective database in the Department of Surgery, Breast Unit University of Milan School of Medicine; and the Department of Nuclear Medicine and Division of Chemoprevention, European Institute of Oncology, Milan, Italy | 4 | Radiation | All patients submitted to breast-conserving surgery received standard external radiotherapy (50 Gy to the whole breast and 10 Gy as a boost to the tumor bed).
Liu, 2003^147^ Country: Taiwan Source: Taichung Veterans General Hospital, Taiwan | 3 | Axillary lymph node dissection | All patients underwent axillary lymph node dissection, nodes were positive in one woman who had positive SNB and was diagnosed with invasive cancer in final biopsy.
Tamhane, 2002^148^ Country: Australia Source: Calvary Hospital and the Australian Capital Territory pathology database | 6 | Mortality or local recurrence | All patients with DCIS were alive without local recurrence or metastasis
Tamhane, 2002^148^ Country: Australia Source: Calvary Hospital and the Australian Capital Territory pathology database | 6 | Adjuvant treatment | No patients with DCIS regardless of SNB status had adjuvant chemotherapy
Tamhane, 2002^148^ Country: Australia Source: Calvary Hospital and the Australian Capital Territory pathology database | 6 | Radiation | No patients with DCIS regardless of SNB status received radiotherapy after mastectomy
Zavotsky, 1999^149^ Country: USA Source: Joyce Eisenberg Keefer Breast Center of the John Wayne Cancer Institute at Saint John’s Health Center, Santa Monica, California | 2 | Axillary lymph node dissection | Completion axillary dissection was performed on both patients with positive SNB and did not find further tumor positive lymph node metastases
Guth, 2008^150^ Country: USA Source: Department of Pathology data in the NYU School of Medicine | 3 | Axillary lymph node dissection | One patient had two additional positive lymph nodes on ALND; one did not undergo complete axillary dissection, and the third patient had negative axillary dissection.

Table F26 Summary of characteristics of included observational studies

Study | Source and Number of Patients, Followup Duration (months), Age (Range), and Outcomes | Key Inclusion/Exclusion Criteria, Strategy to Reduce Bias, Variables | Level of Evidence
Smith; 2006^151^ Country: USA Design: Case-series Active treatment: LR Control treatment: L | Source: SEER-Medicare Number: 3,409 Length of followup (months): 60 Age: Median 74 (≥66) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; all-cause mortality | Inclusion criteria: Women with noninvasive breast cancer without evidence of metastasis, at 66 years or order. Exclusion criteria: Histology not consistent with ductal origin, initial treatment with either biopsy or mastectomy, bilateral lesions, history of prior malignancy, with a second primary cancer diagnosed within 9 months, with inadequate Medicare records, with unknown laterality. Strategy to reduce bias: Multivariate adjustment Variables: Age, race, comobidity, tumor size, histology, grade, treatment, marital status, median income, and urban-rural status. | SEER Registry (retrospecti ve analysis with comparison groups)
Solin, 2005^152^ Country: USA and Europe Design: Case-series Active treatment: LR Control treatment: None. | Source: 10 institutions in 4 countries in North America and Europe Number: 1,003 Length of followup (months): 102 Age: Median 53 (26–86) Outcomes: Ipsilateral DCIS; combined ipsiliateral DCIS and invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality; distant recurrence | Inclusion criteria: Women with unilateral TisN0M0, clinical occult and mammographically detected, receiving breast-conserving surgery followed by definitive breast irradiation>=40Gy, with treatment before 1995, and no adjuvant chemotherapy or hormonal treatment. Exclusion criteria: Paget disease of nipple, prior or concurrent invasive or microinvasive carcinoma of the ipsilateral or contralateral breast, or prior or concurrent malignancy other than DCIS, except for nonmelanoma skin cancer, or receiving <40Gy irradiation. Strategy to reduce bias: stratification and multivariate adjustment Variables: Age, margin, mammographic findings, institution, date, location of primary tumor, and irradiation dose in multivariate analysis. Age, margin, mammographic findings, institution, date, location of primary tumor, and irradiation dose, tumor size, and excision volume in stratification. | IV
Wong, 2006^153^ Country: USA Design: Prospective single-arm trial Active treatment: L Control treatment: None | Source: Dana-Farber/Harvard cancer center Number: 158 Length of followup (months): 43 Age: Median 51 (35–81) Outcomes: Combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Patients with grade 1 or 2 DCIS, less than 2.5cm, without invasion, free margin at least 10mm, seen at the Dana-Farber/Harvard cancer center. Exclusion criteria: Nipple discharge at presentation, a previous breast cancer, simultaneous bilateral DCIS, a history of nonbreast malignancies except squamous or basal cell carcinoma of the skin, or carcinoma in situ of the cervix. Strategy to reduce bias: Stratification Variables: Architecture, nuclear grade, presence of calcification, LCIS, ALH, ADH, necrosis, excision volume, re-excision, and prior core biopsy. | III
Bonnier, 1999^154^ Country: France Design: Case-series Active treatment: M Control treatment: None. | Source: 16 French institutions Number: 575 Length of followup (months): 51 Age: Median 50.7 (22–85) Outcomes: Combined ipsiliateral DCIS and invasive cancer; combined contralateral DCIS and invasive cancer; distant recurrence | Inclusion criteria: Women with DCIS of the breast treated at 16 French institutions between 1983 and 1993. Exclusion criteria: Microscopic axillary LN involvement, prior or concurrent invasive breast cancer, DCIS with micro-infiltration, or malignancy other than breast cancer. Strategy to reduce bias: Stratification Variables: Architecture, tumor size, focality, margin, and treatment. | II-2C
Tunon-de-Lara, 2001^155^ Country: France Design: case-series Active treatment: M, L, or LR Control treatment: None | Source: Regional Cancer Center in Bordeaux Number: 577 Length of followup (months): 86 Age: Mean 51.3 (19–88) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; breast cancer mortalityl all-cause mortality; regional recurrence; distant recurrence | Inclusion criteria: All cases of DCIS surgically treated and histologically diagnosed at authors’ institute from 1971 to 1995. Exclusion criteria: Evidence of invasion or microinvasion, or with contralateral infiltrative carcinoma before DCIS or simultaneously with DCIS. Strategy to reduce bias: Stratification Variables: Age, margin, and treatment | II-2C
de Mascarel, 2000^156^ Country: France Design: Case-series Active treatment: LR Control treatment: L | Source: Regional Cancer Center in Bordeaux Number: 367 Length of followup (months): 71 Age: Median 49 (NA) Outcomes::Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Patients with DCIS treated with breast conservation therapy at the authors’ institute from January 1971 to July 1995. Exclusion criteria: A prior or synchronous infiltrating ductal carcinoma. Strategy to reduce bias: Stratification and multivariate adjustment Variables: Margin, tumor size, pathology grade, and percentage of positive blocks in multivariate analysis. VNPI and treatment in stratification. | II-2C
Cornfield, 2004^157^ Country: USA Design: Case-series Active treatment: L Control treatment: None. | Source: Thomas Jefferson University Hospital Number: 151 Length of followup (months): 65 Age: NA (31–88) Outcomes: Combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Patients with DCIS detected by mammography or as an incidental pathologic finding related to surgery for benign breast disease, negative specimen margins, no evidence of concurrent malignancy elsewhere, and a minimum followup of 15 months. Exclusion criteria: None. Strategy to reduce bias: Stratification and multivariate adjustment Variables: Tumor size and necrosis in multivariate analysis. Architecture, tumor size, nuclear grade, pathology grade, necrosis, other calcification, inflammation, PR status, and bcl-2 status in stratification. | IV
Neuschatz, 2001^158^ Country: USA Design: Case-series Active treatment: LR Control treatment: L | Source: Breast Health Center at New England Medical Center Number: 109 Length of followup (months): 49/54 Age: Median 54 in L group and 56 in LR group (NA) Outcomes: Combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with TisN0M0 treated with breast conservation surgery at the Breast Health Center at New England Medical Center from 1986 to 1997. Exclusion criteria: Women with microinvasion or receiving their treatment and followup elsewhere. Strategy to reduce bias: Stratification Variables: Age, margin, necrosis, tumor size, pathology grade, VNPI, and treatment. | II-2C
Chan, 2001^159^ Country: UK Design: Case-series Active treatment: L Control treatment: None. | Source: Breast Unit of the University Hospital of South Manchester Number: 205 Length of followup (months): 47 Age: Mean 56 (19–82) Outcomes: Combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS treated with BCS, a maximum tumor diameter of 40 mm, histologic slide available for review if the margin width was not declared in the report, and a minimum followup of 1 year. Exclusion criteria: Women with microinvasion. Strategy to reduce bias: Stratification Variables: Margin, tumor size, necrosis, nuclear grade, and treatment. | II-2C
Cutuli, 2001^160^ Country: France Design: Case-series Active treatment: M, L, LR Control treatment: None. | Source: Eight French Cancer Centres Number: 716 Length of followup (months): 91 Age: Median 53.2 (21–87) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; combined contralateral DCIS and invasive cancer; regional recurrence; distant recurrence | Inclusion criteria: DCIS treated in eight cancer certres without evidence of microinvasion or axillary node involvement. Exclusion criteria: None. Strategy to reduce bias: Stratification and multivariate adjustment Variables: Age, method of detection, family history, margin, and treatment in multivariate analysis. Age, margin, tumor size, and architecture in stratification. | II-2C
Joslyn, 2006^161^ Country: USA Design: case-series Active treatment: M, MR, L, LR, R Control treatment: None. | Source: SEER Number: 41.245 Length of followup (months): NA Age: NA (<35, 1.5%, 35–44, 12.7%; 45–54, 25.2%; 55–64, 22.8%; 65–74, 23%; 75–84, 12.6%; ≥85, 2.3%) Outcomes: All-cause mortality | Inclusion criteria: Women diagnosed with primary DCIS in the SEER program from 1973 through 2000. Exclusion criteria: None. Strategy to reduce bias: Stratification and multivariate adjustment Variables: Age, race, site, radiation, and surgery in multivariate analysis. Age, race, radiation, and surgery in stratification. | SEER Registry (retrospecti ve analysis with comparison groups)
Silverstein, 2003^162^ Country: USA Design: Case-series Active treatment: LR Control treatment: L | Source: University of Southern California Number: 706 Length of followup (months): 81 Age: Average 54 (NA) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality; distant recurrence | Inclusion criteria: Women with pure DCIS treated at the authors’ institute. Exclusion criteria: Invasive breast cancer or treated with mastectomy. Strategy to reduce bias: stratification Variables: VNPI in stratification. | II-2C
Schouten van der Velden, 2007^163^ Country: Netherlands Design: Case-series Active treatment: M, MR, L, LR Control treatment: None. | Source: The Cancer Registry of the Comprehensive Cancer Centre East in the Netherlands Number: 798 Length of followup (months): 59 Age: Median 58 (23–91) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with breast cancer classified as in situ between 1989 and 2003. Exclusion criteria: Patients with a history of or a simultaneous invasive breast cancer and other malignancies (except for nonmelanoma skin cancer and in situ cervical carcinoma), or medical records not available for review. Strategy to reduce bias: Stratification and multivariate adjustment Variables: Age, method of detection, comedonecrosis, margin, and treatment in multivariate analysis. Age, method of detection, grade, comedonecrosis, tumor size, re-excision, and margin in stratification. | Cancer Registry (retrospecti ve analysis with comparison groups)
Warren, 2005^164^ Country: USA Design: Case-series Active treatment: LR Control treatment: L | Source: SEER Number: 1,103 Length of followup (months): 91 Age: NA Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; breast cancer mortality | Inclusion criteria: Women diagnosed with DCIS from the SEER registries, in 1991 or 1992 (only in 1992 from Los Angeles County), and treated with BCS. Exclusion criteria: Women with a previous diagnosis of cancer except for nonmelanoma skin cancer, or with simultaneous cancer diagnoses. Strategy to reduce bias: Multivariate analysis Variables: Various demographic and clinical factors in multivariate analysis. Factors being studied include age, race, marital status, Charlson comorbidity score, grade, necrosis, tumor size, margin, radiation, and tamoxifen treatment. | SEER Registry (retrospecti ve analysis with comparison groups)
Smith, 2006^165^ Country: USA Design: Case-series Active treatment: M, LR, L Control treatment: None. | Source: SEER Number: 14,202 Length of followup (months): 28.8 Age: Mean 58 (≥18) Outcomes: Combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS between 1996 and 2001 in the SEER program. Exclusion criteria: Women less than 18 years old, a prior malignancy, with nonpathologically confirmed tumors, missing tumor size or grade, or unknown/missing radiotherapy status or surgery status. Strategy to reduce bias: Stratification and multivariate adjustment Variables: Prognostic score (including age, tumor size, and grade), race, site, and treatment in multivariate analysis. Prognostic score and site in stratification. | SEER Registry (retrospecti ve analysis with comparison groups)
Kerlikowske, 2003^166^ Country: USA Design: case-series Active treatment: L Control treatment: None. | Source: SEER program of Northern California Number: 1,036 Length of followup (months): 77.9 Age: NA (≥40) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; breast cancer mortality; regional recurrence; distant recurrence | Inclusion criteria: Women ages 40 years or order, DCIS treated by lumpectomy alone in SEER program of Northern California. Exclusion criteria: Women treated by mastectomy or lumpectomy and radiation within 6 months of the initial diagnosis, a prior diagnosis of breast cancer, died within 6 months of the initial diagnosis, or invasive cancer on standardized pathology review. Of the 1,339 eligible participants, 82 could not be located, 24 did not speak fluent English, Cantonese, Spanish, or Russian, 193 refused to participate, and 4 had a doctor’s request not to be contacted. Strategy to reduce bias: Stratification Variables: Age, race, method of detection, menopausal status, family history, BMI, oral contraceptive use, and postmenopausal hormone therapy in stratification. | SEER Registry (retrospecti ve analysis without comparison groups)
Rodrigues, 2002^167^ Country: USA Design: Case-series Active treatment: LR Control treatment: None. | Source: Yale University School of Medicine Number: 230 Length of followup (months): 98.4 Age: Median 53 (29–86) Outcomes: Iipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality | Inclusion criteria: Women with pure DCIS treated with LR at the authors’ institute. Exclusion criteria: Women with concurrent invasive or microinvasive carcinoma. Strategy to reduce bias: Stratification Variables: Age, method of detection, family history, re-excision, architecture, necrosis, grade, margin, tamoxifen treatment, and contralateral breast cancer in stratification. | IV
Jeruss, 2006^168^ Country: USA Design: Case-series Active treatment: L + APBI Control treatment: None. | Source: A registry trial to assess the MammoSite applicator Number: 158 Length of followup (months): 7.35 Age: Mean 64 (40–87) Outcomes: Combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS up to 4.5cm (measured by mammography), negative nodal status, negative surgical margin status, applicator placement within 10 weeks of final lumpectomy procedure, and a post-lumpectomy cavity with one dimension of at least 3cm. Exclusion criteria: Women with collagen vascular disease, or receiving a boost of radiation. Strategy to reduce bias: None. Variables: Crude rate only. | Registry (retrospecti ve analysis without comparison groups)
Hwang, 1998^169^ Country: USA Design: Case-series Active treatment: LR or L Control treatment: None. | Source: DCIS treated by BCS at MSKCC. Number: 126 Length of followup (months): NA Age: Median 61 (31–89) Outcomes: Combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS treated by BCS at MSKCC. Exclusion criteria: Women with incomplete resection volume data. Strategy to reduce bias: Stratification Variables: Excision volume and radiation in stratification. | II-2C
Ottesen, 1992^170^ Country: USA Design: Case-series Active treatment: L Control treatment: None. | Source: DBCG 82-IS (Danish nationwide prospective study of in situ carcinoma of the breast) Number: 112 Length of followup (months): 53 Age: Median 48 (29–81) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; combined contralateral DCIS and invasive cancer; all-cause mortality; regional recurrence | Inclusion criteria: Women with DCIS in the protocol DBCG 82-IS from 1982 to 1987 and treated with excision only. Exclusion criteria: Cases with microinvasion, with previous malignant disease (except in situ cervical cancer and skin cancer), or missing for histopathological review. Strategy to reduce bias: Stratification Variables: Architecture, growth pattern, tumor size, nuclear size, comedonecrosis, margin, surgery type, and method of detection in stratification. | DBCG 82-IS Trial (retrospecti ve analysis without comparison groups)
Kestin, 2000^171^ Country: USA Design: Case-series Active treatment: LR Control treatment: None | Source: Patients at William Beaumont Hospital, Royal Oak, Michigan Number: 132 Length of followup (months): 84 Age: NA (20% <45 years) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; contralateral DCIS; contralateral invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality | Inclusion criteria: Women with DCIS (Tis N0 M0) treated with lumpectomy followed by radiation therapy, and only mammographicallly detected tumors with complete histologic review, at the authors’ institute. Exclusion criteria: Cases with invasive or microinvasive carcinoma of the breast, initial detection by any method other than mammography, or incomplete pathologic review. Strategy to reduce bias: Multivariate analysis Variables: Age, Number of slides with DCIS, margin, tumor size, nuclear grade, necrosis, and number of DCIS and COL foci ≤5mm from the margin in multivariate analysis. Age, pre-RT mammography, reexcision status, margin, calcification, nuclear grade, necrosis, No of slides with DCIS, and No of COL foci ≤5mm margin in stratification. | IV
Harris, 2000^172^ Country: USA Design: Case-series Active treatment: LR Control treatment: None | Source: Patients in the department of Radiation Oncology at University of Pennsylvania. Number: 146 Length of followup (months): 85.2 Age: NA (8.5%, <40; 26.7%, 40–49; 65.1%, ≥50) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality | Inclusion criteria: Women with a pathologic diagnosis of unilateral DCIS as their first diagnosis of any breast cancer in the authors’ institute between 1978 and 1995. Exclusion criteria: Cases with microinvasive cancers or prior contralateral invasive or noninvasive breast cancers. Strategy to reduce bias: Stratification Variables: Age, axillary LN dissection status, and family history in stratification. | IV
Boland, 2003^173^ Country: UK Design: Case-series Active treatment: L, LR, LT, or LRT Control treatment: None | Source: Breast Unit of the University Hospital of South Manchester Number: 237 Length of followup (months): 47 Age: Median 56 (19–80) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; contralateral DCIS; contralateral invasive cancer; combined contralateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS treated with BCS at authors’ institute. Exclusion criteria: Women with microinvasion, undeterminable excision margins, or lost to followup. Strategy to reduce bias: multivariate analysis Variables: Margin, grade, and tumor size in multivariate analysis. Margin, grade, tumor size, VN score, and age in stratification. | II-2C
Vicini, 2000^174^ Country: USA Design: case-series Active treatment: LR Control treatment: None | Source: Patients at William Beaumont Hospital, Royal Oak, Michigan Number: 148 Length of followup (months): 86.4 Age: NA (20.9% <45; 79.1% ≥45) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality | Inclusion criteria: Women with DCIS (Tis N0 M0) treated with lumpectomy followed by radiation therapy, with complete histologic review, at the authors’ institute. Exclusion criteria: Cases with invasive or microinvasive carcinoma of the breast, or incomplete pathologic review. Strategy to reduce bias: Stratification and multivariate adjustment Variables: Age, calcification, number of slide with DCIS, margin, number of DCIS or COL foci ≤5mm from margin, tumor size, nuclear grade, necrosis, method of detection, and re-excision volume (or excision volume) in multivariate analysis. Age, method of detection, reexcision status, volume of initial excision, volume of reexcision, total volume of excision, margin, slides with DCIS, calcification with DCIS, nuclear grade, necrosis, pre-RT mammography, and DCIS, ADH/COL and DCIS, or COL and DCIS ≤5mm from margin in stratification. | IV
Vicini, 2008^175^ Country: USA Design: Case-series Active treatment: L + APBI Control treatment: None | Source: Patients in the MammoSite Breast Brachytherapy Registry Trial Number: 194 Length of followup (months): 28.6 Age: Median 62.1 (40.7–88) Outcomes: Combined ipsiliateral DCIS and invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality; regional recurrence; distant recurrence | Inclusion criteria: Women with early stage breast cancer who were undergoing BCS were treated with Mammosite device to deliver APBI. Only data of DCIS cases are abstracted. Exclusion criteria: None Strategy to reduce bias: None Variables: None | Registry (retrospecti ve analysis without comparison groups)
Dawood, 2008^176^ Country: USA Design: Case-series Active treatment: M, MR, LRT, LT, LR, or L Control treatment: None | Source: M.D. Anderson Cancer Center Number: 799 Length of followup (months): 34.8 Age: Median 54 (22–88) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; combined contralateral DCIS and invasive cancer; all-cause mortality | Inclusion criteria: Women with DCIS in MDACC breast cancer database. Exclusion criteria: Patients with a prior history of invasive breast cancer, or with suspicious foci of microinvasion at the time of DCIS diagnoses. Strategy to reduce bias: Stratification Variables: Age, race, tumor size, nuclear grade, ER/PR status, menopause, hormone therapy, radiation, and surgery type in stratification. | II-2C
Ernster, 2000^177^ Country: USA Design: Case-series Active treatment: NA Control treatment: None | Source: SEER Number: 7,072 Length of followup (months): 99 Age: NA (≥40) Outcomes: Breast cancer mortality; all-cause mortality | Inclusion criteria: White and black women age 40 and older with newly diagnosed DCIS from 1978 to 1989 in the SEER program. Exclusion criteria: Cases of LCIS, previous invasive breast cancer, any invasive breast cancer within the 2 months following the index diagnosis, or DCIS diagnosed only at autopsy or only on the basis of death certificate report. Strategy to reduce bias: stratification Variables: Age and year of diagnosis in stratification. | SEER Registry (retrospective analysis without comparison groups)
Schairer, 2004^178^ Country: USA Design: Case-series Active treatment: NA Control treatment: None | Source: SEER Number: 45,854 Length of followup (months): white: <50, 96; 50–59, 92.4; 60–69, 90; ≥70, 63.6 black: <50, 76.8; 50–59, 70.8; 60–69, 69.6; ≥70, 54 Age: NA Outcomes: Breast cancer mortality; all-cause mortality | Inclusion criteria: White and black women firstly diagnosed breast cancer from 1973 through 2000 in SEER registries. Exclusion criteria: Cases with no followup time, errors in cause-of-death codes, breast cancer first identified on death certificate or by autopsy, or other and unknown races. Strategy to reduce bias: Stratification Variables: Age and race in stratification. | SEER Registry (retrospective analysis without comparison groups)
Sumner, 2007^56^ Country: USA Design: Case-series Active treatment: NA Control treatment: None | Source: The Florida Cancer Data System Number: 23,810 Length of followup (months): 101 Age: Median 64 (18–103) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; all-cause mortality | Inclusion criteria: Women with DCIS in the Florida Cancer Data System between 1981 and 2001. Exclusion criteria: Women with evidence of invasive breast cancer. Strategy to reduce bias: None. Variables: None. | Registry (retrospective analysis without comparison groups)
Habel, 2004^179^ Country: USA Design: Case-series Active treatment: L or LR Control treatment: None | Source: NSABP B-17 Number: 392 Length of followup (months): 132 Age: NA [≤49 (32.7%); 50–59 (32.4%); ≥60 (34.9%)] Outcomes: Ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; combined contralateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS receiving a lumpectomy, 56 days or less between surgery and randomization, and histologically tumor-free margins of the resected specimen. Films were available in 504 women. Exclusion criteria: Past history of cancer except in situ carcinoma of cervix or squamous-cell or basal-cell carcinoma of the skin, and tumor-positive axillary nodes on clinical examination. Poor mammogram quality, or without imaging the entire area of the breast. Strategy to reduce bias: Stratification and multivariate analysis Variables: Mammographic density in stratification. | RCT (retrospecti ve analysis)
Vicini, 2001^180^ Country: USA Design: Case-series Active treatment: LR Control treatment: None | Source: Patients at William Beaumont Hospital, Royal Oak, Michigan Number: 148 Length of followup (months): 86.4 Age: NA (<45, 31/148; ≥45 117/148) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; contralateral DCIS; contralateral invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality | Inclusion criteria: Women with DCIS treated with lumpectomy followed by radiation therapy at authors’ institute, and with complete pathologic review. Exclusion criteria: Invasive or microinvasive carcinoma or incomplete pathologic review. Strategy to reduce bias: stratification and multivariate analysis Variables: Age, calcifications, number of slides with DCIS, margin, numbers of DCIS/COL foci ≤5mm from margin, tumor size, nuclear grade, comedonecrosis, and total volume of excision in multivariate analysis. Age, method of detection, re-excision, calcifications, number of slides with DCIS, margin, numbers of DCIS/COL foci ≤5mm from margin, tumor size, nuclear grade, comedonecrosis, and total volume of excision in stratification. | IV
Vargas, 2005^181^ Country: USA Design: Case-series Active treatment: MR or M Control treatment: None | Source: Patients at William Beaumont Hospital, Royal Oak, Michigan Number: 410 Length of followup (months): 84 Age: NA (<45:18.3%) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality; distant recurrence | Inclusion criteria: Women with DCIS treated at authors’ institute. Exclusion criteria: Invasive or microinvasive carcinoma. Strategy to reduce bias: Stratification and multivariate analysis Variables: Age, pre-radiation mammogram, mass in mammogram, boost energy, and residual DCIS at re-excision in multivariate analysis. Age, premenopausal status, mammogram characteristics, pre-radiation mammogram, residual DCIS in re-excision, margin, nuclear grade, treatment, and boost energy in stratification. | II-2C
Warneke, 1995^182^ Country: USA Design: Case-series Active treatment: M Control treatment: L | Source: Patients from the tumor registry at University Medical Center and Tucson Medical Center in Tucson, AZ. Number: 124 Length of followup (months): 43 Age: Mean 60 (33–81) Outcomes: Combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS treated from the tumor registry at University Medical Center and Tucson Medical Center in Tucson, AZ Exclusion criteria: Invasive or LCIS were excluded Strategy to reduce bias: Stratification Variables: Necrosis, margin in stratification | Registry (retrospective analysis with comparison groups)
Fish, 1998^183^ Country: Canada Design: Case-series Active treatment: M Control treatment: BCS | Source: Patients treated at Henrietta Banting Breast Centre Number: 124 Length of followup (months): 60 Age: NA (in L group, 6/88 ≤39, 25/88; 40–49, 30/88; 50–64, 27/88 ≥65) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; contralateral DCIS; contralateral invasive cancer; regional recurrence; distant recurrence | Inclusion criteria: Patients with first primary DCIS diagnosed at authors’ institute. Exclusion criteria: None. Strategy to reduce bias: Stratification and multivariate analysis Variables: Not specified in multivariate analysis. Age, method of detection, tumor size, architecture, necrosis, nuclear grade, calcification, margin, overall percentage parenchymal involvement, and presence of uninvolved intervening duct in stratification. | II-2C
Liberman, 1997^184^ Country: USA Design: Case-series Active treatment: LR or L Control treatment: None | Source: Patients treated at Memorial Sloan-Kettering Cancer Center Number: 162 Length of followup (months): 75 Age: Median 60 (20–89) Outcomes: Combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Patients with DCIS treated at authors’ institute with BCS from 1978 to 1990 and available followup data. Exclusion criteria: None. Strategy to reduce bias: None. Variables: None. | IV
Hwang, 2007^185^ Country: USA Design: Case-series Active treatment: L or LR Control treatment: None | Source: Patients from Breast Cancer Surveillance Consortium (BCSC) Number: 3,274 Length of followup (months): 39 Age: Mean 58 (30–93) Outcomes: Ipsilateral invasive cancer; contralateral DCIS; contralateral invasive cancer | Inclusion criteria: Women at BCSC sites with DCIS diagnosed between 1993 and 2005, with a breast density measurement recorded prior to diagnosis. Exclusion criteria: Women with a diagnosis of LCIS, previous breast cancer history, a diagnosis of ipsilateral invasive breast cancer within 60 days of DCIS diagnosis, or receiving mastectomy treatment. Strategy to reduce bias: Multivariate analysis Variables: Age, radiation status, and breast density in multivariate analysis. | BCSC Registry (retrospective analysis with comparison groups)
Ringberg, 2000^186^ Country: Sweden Design: Case-series Active treatment: M Control treatment: BCS | Source: Population based Regional Tumor Registry in Lund Number: 306 Length of followup (months): 63 Age: Median 59 (29–95) Outcomes: Combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS treated at Regional Tumor Registry in Lund between 1987 and 1991. Exclusion criteria: LCIS or microinvasive carcinoma Strategy to reduce bias: Stratification Variables: Method of detection, margin, tumor size, nuclear grade, VN grade, and growth pattern in stratification. | Registry (retrospective analysis with comparison groups)
Ringberg, 2001^187^ Country: Sweden Design: Case-series Active treatment: L Control treatment: None | Source: Population based Regional Tumor Registry in Lund Number: 121 Length of followup (months): 62 Age: Median 60 (29–83) Outcomes: Combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS treated at Regional Tumor Registry in Lund between 1987 and 1991. Exclusion criteria: LCIS or microinvasive carcinoma Strategy to reduce bias: Stratification and multivariate analysis Variables: CBI-7, grade, and growth pattern in multivariate analysis. CBI-7, ER, PR, c-erbB-2, bcl-2, P53, ploidy status, Ki 67, nuclear grade, and growth pattern in stratification. | Registry (retrospective analysis without comparison groups)
Cutuli, 2002^188^ Country: France Design: Case-series Active treatment: LR Control treatment: L | Source: Nine French Cancer Centres Number: 705 Length of followup (months): 84 Age: Mean 53.7 (NA) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; combined contralateral DCIS and invasive cancer; regional recurrence; distant recurrence | Inclusion criteria: DCIS treated in nine cancer certres without evidence of microinvasion or axillary node involvement. Exclusion criteria: Patients underwent mastectomy Strategy to reduce bias: Stratification and multivariate adjustment Variables: Radiation, age, tumor stage, margin, and family history in multivariate analysis. Age, method of detection, tumor size, architecture, margin, and type of surgery in stratification. | II-2C
Deutsch, 2007^189^ Country: USA Design: Case-series Active treatment: LRT or LR Control treatment: None | Source: B-24 Number: 1,804 Length of followup (months): NA Age: NA Outcomes: Other | Inclusion criteria: Women with DCIS, no sign of invasive cancer, 56 days or less between surgery and randomization. Exclusion criteria: Past history of cancer except in situ carcinoma of cervix or squamous-cell or basal-cell carcinoma of the skin, and life expectancy less than 10 years. Strategy to reduce bias: None Variables: None | RCT (retrospective analysis)
Silverstein, 2003^190^ Country: USA Design: Case-series Active treatment: LR Control treatment: L | Source: University of Southern California Number: 660 Length of followup (months): 88 Age: NA Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; breast cancer mortality; distant recurrence | Inclusion criteria: Women with pure DCIS treated by BCS at the authors’ institute. Exclusion criteria: Women treated with mastectomy. Strategy to reduce bias: Stratification Variables: Margin in stratification. | II-2C
MacDonald, 2005^191^ Country: USA Design: Case-series Active treatment: L Control treatment: None | Source: University of Southern California Number: 445 Length of followup (months): 57 Age: NA Outcomes: Combined ipsiliateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality; distant recurrence | Inclusion criteria: Women with pure DCIS treated with excision alone at the authors’ institute. Exclusion criteria: None. Strategy to reduce bias: Stratification and multivariate adjustment Variables: Margin, age, nuclear grade, tumor size, and necrosis in multivariate analysis. Age, margin, nuclear grade, tumor size, and necrosis in stratification. | IV
MacDonald, 2006^192^ Country: USA Design: Case-series Active treatment: LR Control treatment: L | Source: University of Southern California Number: 272 Length of followup (months): 53 Age: NA Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with pure DCIS treated with BCS with margins of 10mm or greater at the authors’ institute. Exclusion criteria: Microinvasion. Strategy to reduce bias: Multivariate analysis Variables: Age, nuclear grade, tumor size, and necrosis with radiation therapy in bivariate analysis. | II-2C
Nakamura, 2002^193^ Country: USA Design: Case-series Active treatment: LR Control treatment: None | Source: University of Southern California Number: 260 Length of followup (months): 105 Age: Median 53 (NA) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; breast cancer mortality; distant recurrence | Inclusion criteria: Women with pure DCIS treated with excision and radiation at the authors’ institute. Exclusion criteria: None Strategy to reduce bias: Stratification Variables: Margin, tumor size, nuclear grade, radiation status, and Lagios’ criteria in stratification. | IV
Silverstein, 1996^194^ Country: USA Design: Case-series Active treatment: LR Control treatment: L | Source: The Breast Center in Van Nuys, California and the Children’s Hospital in San Francisco Number: 333 Length of followup (months): 79 Age: NA Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; breast cancer mortality; distant recurrence | Inclusion criteria: Women with pure DCIS treated with BCS at the authors’ institute. Exclusion criteria: Microinvasion. Strategy to reduce bias: Stratification Variables: VN grade in stratification. | II-2C
Silverstein, 1995^195^ Country: USA Design: Case-series Active treatment: M, LR or L Control treatment: None | Source: The Breast Center in Van Nuys, California Number: 425 Length of followup (months): 78 Age: NA Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; breast cancer mortality distant recurrence | Inclusion criteria: Women with pure DCIS treated at the authors’ institute. Exclusion criteria: Microinvasion. Strategy to reduce bias: Stratification Variables: VNPI in stratification. | II-2C
Silverstein, 1995^196^ Country: USA Design: Case-series Active treatment: M Control treatment: LR | Source: The Breast Center in Van Nuys, California Number: 300 Length of followup (months): 78 Age: Median 50 (NA) Outcomes: ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; breast cancer mortality | Inclusion criteria: Women with pure DCIS treated at the authors’ institute. Exclusion criteria: Microinvasion. Strategy to reduce bias: Stratification and multivariate analysis Variables: VN grade in stratification. | II-2C
Silverstein, 1992^197^ Country: USA Design: case-series Active treatment: M, LR, or L Control treatment: None | Source: The Breast Center in Van Nuys, California Number: 227 Length of followup (months): 56 Age: Average 52 (27–82) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; all-cause mortality | Inclusion criteria: Women with pure DCIS treated at the authors’ institute. Exclusion criteria: Microinvasion. Strategy to reduce bias: Stratification Variables: Architecture in stratification. | II-2C
Silverstein, 1991^198^ Country: USA Design: Case-series Active treatment: M or LR Control treatment: None | Source: The Breast Center in Van Nuys, California Number: 213 Length of followup (months): 51 Age: Mean 52 (27–82) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality; distant recurrence | Inclusion criteria: Women with pure DCIS treated by M or LR at the authors’ institute. Exclusion criteria: None. Strategy to reduce bias: Stratification Variables: Architecture in stratification. | II-2C
Amichetti, 1997^199^ Country: Italy Design: Case-series Active treatment: LR Control treatment: None | Source: 10 radiation oncology departments of north-east Italy Number: 139 Length of followup (months): 81 Age: Median 50 (28–88) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; contralateral DCIS; contralateral invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality; regional recurrence; distant recurrence | Inclusion criteria: All patients with DCIS referred to 10 radiation oncology departments of the north of Italy from 1980 to 1990. Exclusion criteria: None. Strategy to reduce bias: None. Variables: None. | IV
Chuwa, 2008^200^ Country: Singapore Design: Case-series Active treatment: M or MT Control treatment: BCS | Source: National Cancer Center in Singapore Number: 170 Length of followup (months): 86 Age: Median 52.5 (28–85) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality; distant recurrence | Inclusion criteria: Women with DCIS stage Tis N0 M0, treated at the authors’ institute Exclusion criteria: Invasive or microinvasive carcinoma or history of previous history of breast cancer or DCIS Strategy to reduce bias: Multivariate analysis Variables: Age, menopausal status, symptom, grade, size, hormone receptor status, necrosis, margin, radiation, and tamoxifen in multivariate analysis. | II-2C
Mirza, 2000^201^ Country: USA Design: Case-series Active treatment: LR Control treatment: None | Source: MD Anderson Cancer Center Number: 109 Length of followup (months): 132 in DCIS, 144 in DCIS with microinvasion Age: Median 52 in DCIS and 46 in microinvasion (26–74) Outcomes: Combined ipsiliateral DCIS and invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality; distant recurrence | Inclusion criteria: Women with DCIS treated at authors’ institute. Exclusion criteria: Patients without radiotherapy, or with pro-op chemotherapy or hormone therapy, or with a history of another primary malignancy except basal cell carcinoma or CIS of cervix Strategy to reduce bias: Stratification Variables: Microinvasion status in stratification. | IV
Chagpar, 2003^202^ Country: USA Design: Case-series Active treatment: L, LR, LT, or LRT Control treatment: None | Source: MD Anderson Cancer Center Number: 109 Length of followup (months): 11.4 Age: Median 55 (34–81) Outcomes: Combined ipsiliateral DCIS and invasive cancer; breast cancer mortality; distant recurrence | Inclusion criteria: Women with DCIS diagnosed by core needle biopsy and received BCS in authors’ institute Exclusion criteria: Patients with excisional biopsy prior to referral, receiving mastectomy, for second opinion only, or refusing surgery. Strategy to reduce bias: None Variables: None | IV
Miller, 2001^203^ Country: Canada Design: Case-series Active treatment: M, LR, or L Control treatment: None | Source: The Henrietta Banting Breast Center Number: 124 Length of followup (months): 60 for L and 80.4 for M Age: NA 8 ≤39 38; 40–49, 45; 50–64, 33; ≥65 (NA) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; contralateral invasive cancer | Inclusion criteria: Women with DCIS, no previous breast or other malignancy, and a detailed followup Exclusion criteria: On review without DCIS, or previous carcinoma, no followup, or primary histology slides unavailable Strategy to reduce bias: stratification and multivariate adjustment Variables: Methods of detection and parenchymal involved in multivariate analysis. Age, method of detection, tumor size, architecture, necrosis, nuclear grade, calcification, margin, and overall percentage parennchymal involvement in stratification. | II-2C
Adepoju, 2006^204^ Country: USA Design: Case-series Active treatment: LR or L Control treatment: None | Source: MD Anderson Cancer Center Number: 310 Length of followup (months): 103.2 Age: Median 55 (25–85) Outcomes: Combined ipsiliateral DCIS and invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality | Inclusion criteria: Women with DCIS treated at authors’ institute. Exclusion criteria: None. Strategy to reduce bias: Stratification Variables: Age, race, family history, margin, tumor size, nuclear grade, necrosis, microinvasion, and ADH or LN status in stratification. | II-2C
Takeda, 2001^205^ Country: Japan Design: Case-series Active treatment: LR or L Control treatment: None | Source: Keio University Hospital Department of Radiology Number: 114 Length of followup (months): 46.7 Age: Median 46 (26–81) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; breast cancer mortality | Inclusion criteria: Women with DCIS treated by BCS at authors’ institute Exclusion criteria: None Strategy to reduce bias: None Variables: None | II-2C
Ben-David, 2007^206^ Country: USA Design: Case-series Active treatment: LR or LRT Control treatment: None | Source: Department of Radiation Oncology at the University of Michigan Number: 198 Length of followup (months): 74.4 Age: Median 53.5 (30–83) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; contralateral invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality; distant recurrence | Inclusion criteria: Women with DCIS treated at the authors’ institute Exclusion criteria: A prior diagnosis of invasive breast cancer Strategy to reduce bias: Stratification and multivariate analysis Variables: Not specified in multivariate analysis. Age, race, menopausal status, patient’s weight, family history, method of detection, tumor size, architecture, nuclear grade, margin, tamoxifen treatment, radiation dose, excision volume, and residual microcalcification in mammogram in stratification. | IV
Asjoe, 2007^207^ Country: Belgium Design: Case-series Active treatment: M, LR, or L Control treatment: None | Source: The University Hospital, Antwerp Number: 104 Length of followup (months): 36 Age: Median 53.5 (29–79) Outcomes: Combined ipsiliateral DCIS and invasive cancer; regional recurrence; distant recurrence | Inclusion criteria: Women with DCIS and/or microinvasive treated at the authors’ institute Exclusion criteria: A prior diagnosis of invasive breast cancer Strategy to reduce bias: Stratification Variables: Margin, age, tumor size, nuclear grade, VN grade, and VNPI in stratification. | II-2C
Kestin, 2000^208^ Country: USA Design: Case-series Active treatment: LR Control treatment: L | Source: Patients at William Beaumont Hospital, Royal Oak, Michigan Number: 177 Length of followup (months): 84 Age: NA (18% <45) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; contralateral DCIS; contralateral invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality; distant recurrence | Inclusion criteria: Women with DCIS (Tis N0 M0) treated with BCS with or without radiation, and only mammographicallly detected tumors with complete histologic review, at the authors’ institute. Exclusion criteria: Cases with invasive or microinvasive carcinoma of the breast, initial detection by any method other than mammography, or incomplete pathologic review. Strategy to reduce bias: Stratification Variables: Margin, pre-RT mammography, reexcision, age, nuclear grade, comedonecrosis, and VNPI in stratification. | II-2C
Goldstein, 2000^209^ Country: USA Design: Case-series Active treatment: LR Control treatment: None | Source: Patients at William Beaumont Hospital, Royal Oak, Michigan Number: 132 Length of followup (months): 84 Age: Median 56 (31–84) Outcomes: Combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS (Tis N0 M0) treated with lumpectomy followed by radiation therapy, and only mammographicallly detected tumors with complete histologic review, at the authors’ institute. Exclusion criteria: Cases with invasive or microinvasive carcinoma of the breast, initial detection by any method other than mammography, or incomplete pathologic review. Strategy to reduce bias: stratification and multivariate analysis Variables: Age, number of slides with DCIS, number of DCIS or TDLU within 4.2 mm of final margin, nuclear grade, microcalcification, and tumor size in multivariate analysis. Architecture, necrosis, nuclear grade, growth pattern, margin, and reexcision in stratification. | IV
Lee, 2006^210^ Country: USA Design: Case-series Active treatment: M, LR or L Control treatment: None | Source: The Breast Center in Van Nuys, California Number: 1,236 Length of followup (months): 72 Age: NA Outcomes: Ipsilateral DCIS; Ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality; distant recurrence | Inclusion criteria: Women with pure DCIS treated at the authors’ institute. Exclusion criteria: Microinvasion Strategy to reduce bias: None Variables: None | II-2C
Meijnen, 2008^211^ Country: Netherlands Design: Case-series Active treatment: M, LR, or L Control treatment: None | Source: Netherland Cancer Institute Number: 504 Length of followup (months): 80.4 Age: Median 51 (22–81) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality; distant recurrence | Inclusion criteria: Women with DCIS treated at the authors’ institute Exclusion criteria: Invasive or microinvasive carcinoma or history of previous history of breast cancer Strategy to reduce bias: Stratification and multivariate analysis Variables: Age, method of detection, treatment, margins, and pathologic grades in multivariate analysis. Age, architecture, and tumor size in stratification. | II-2C
Di Saverio, 2008^212^ Country: Italy Design: Case-series Active treatment: LR or L Control treatment: None | Source: Breast Unit of the Department of Surgery, S. Orsola Malpighi University Hospital in Bologna, Italy Number: 259 Length of followup (months): 130 Age: NA Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality | Inclusion criteria: Women with DCIS treated by BCS with or without radiotherapy at authors’ institute Exclusion criteria: None Strategy to reduce bias: Stratification Variables: Margin, age, method of detection, HRT, tumor size, family history, VN grade, and VNPI in stratification. | II-2C
Cataliotti, 1992^213^ Country: Italy Design: Case-series Active treatment: M, LR or L Control treatment: None | Source: Department of Surgery and Radiotherapy of the University and General Hospital of Caraggi in Florence Number: 183 Length of followup (months): 94 Age: Mean 54 (31–83) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS treated at the authors’ institute Exclusion criteria: Paget’s disease or positive LN Strategy to reduce bias: Stratification Variables: Margin, architecture, and tumor size in stratification | II-2C
Ciatto, 1990^214^ Country: Italy Design: Case-series Active treatment: M Control treatment: LR | Source: 11 institutions in Italy Number: 350 Length of followup (months): 66 Age: Mean 52.8 (26–85) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality | Inclusion criteria: Women with DCIS treated at the authors’ institute Exclusion criteria: Axillary LN involvement Strategy to reduce bias: None Variables: None | II-2C
MacAusland, 2007^215^ Country: USA Design: Case-series Active treatment: L Control treatment: None | Source: 4 institutions (Women and Infant’s Hospital, Rhode Island Hospital, St. Elizabeth’s Medical Center, and Tufts-New England Medical Center Number: 222 Length of followup (months): 55.2 Age: Mean 57 (31–85) Outcomes: Combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with mammographically detected DCIS were treated with excision alone at the authors’ institutes Exclusion criteria: None Strategy to reduce bias: Stratification Variables: Margin, tamoxifen, VN grade, and VNPI in stratification. | IV
Sahoo, 2005^216^ Country: USA Design: Case-series Active treatment: LR Control treatment: None | Source: University of Chicago Number: 103 Length of followup (months): 63 Age: NA Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS treated with BCS and radiation therapy at authors’ institute Exclusion criteria: Limited information provided in the pathology reports Strategy to reduce bias: Stratification and multivariate analysis Variables: Margin, age, nuclear grade, necrosis, and tumor size in multivariate analysis. Margin in stratification. | IV
Amichetti, 1999^217^ Country: Italy Design: Case-series Active treatment: LR Control treatment: None | Source: 15 Radiation Oncology Departments mainly located in the north-east of Italy Number: 112 Length of followup (months): 68 Age: Median 50 (32–72) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer combined ipsiliateral DCIS and invasive cancer; contralateral DCIS; contralateral invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality | Inclusion criteria: Women with mammographically detected subclinical DCIS treated with BCS and radiation therapy at authors’ institute Exclusion criteria: Microinfiltration or prior or concurrent invasive carcinoma Strategy to reduce bias: None Variables: None | IV
Dimpfl, 1996^218^ Country: German Design: Case-series Active treatment: M, LR, or L Control treatment: None | Source: the Universittats- Frauenklinik Berlin-Charlottenberg and the I. Frauenklinik der Universitat Munchen Number: 161 Length of followup (months): 78.4 Age: Average 56.7 (26–87) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; breast cancer mortality; distant recurrence | Inclusion criteria: Women with DCIS stage Tis treated at the authors’ institute Exclusion criteria: None Strategy to reduce bias: None Variables: None | II-2C
Vapiwala, 2006^219^ Country: USA Design: Case-series Active treatment: LR Control treatment: None | Source: the University of Pennsylvania Number: 192 Length of followup (months): 74.4 Age: Median 57 (34–82) Outcomes: Combined ipsiliateral DCIS and invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality; regional recurrence; distant recurrence | Inclusion criteria: Women with unilateral Tis N0 M0, clinical occult and mammographically detected, receiving breast-conserving surgery followed by definitive breast irradiation ≥50Gy, with treatment before 2000, and no adjuvant chemotherapy or hormonal treatment. Exclusion criteria: Paget disease of nipple, prior or concurrent invasive or microinvasive carcinoma of the ipsilateral or contralateral breast, or prior or concurrent malignancy other than DCIS, except for nonmelanoma skin cancer, or receiving <50Gy irradiation. Strategy to reduce bias: Stratification Variables: Margin and re-excision in stratification. | IV
Solin, 1996^220^ Country: USA and Europe Design: Case-series Active treatment: LR Control treatment: None | Source: 10 institutions in 4 countries in North America and Europe Number: 110 Length of followup (months): 111.6 Age: Median 51 (26–75) Outcomes: Combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with unilateral Tis N0 M0, clinical occult and mammographically detected, receiving breast-conserving surgery followed by definitive breast irradiation ≥40Gy, with treatment before 1995, and no adjuvant chemotherapy or hormonal treatment. Exclusion criteria: Paget disease of nipple, prior or concurrent invasive or microinvasive carcinoma of the ipsilateral or contralateral breast, or prior or concurrent malignancy other than DCIS, except for nonmelanoma skin cancer, or receiving <40Gy irradiation. Strategy to reduce bias: Stratification Variables: Architecture, nuclear grade, and necrosis in stratification. | IV
Solin, 1996^221^ Country: USA and Europe Design: Case-series Active treatment: LR Control treatment: None | Source: 10 institutions in 4 countries in North America and Europe Number: 270 Length of followup (months): 123.6 Age: median 50 (26–82) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality; distant recurrence | Inclusion criteria: Women with unilateral TisN0M0, receiving breast-conserving surgery followed by definitive breast irradiation Exclusion criteria: Paget disease of nipple, prior or concurrent invasive or microinvasive carcinoma of the ipsilateral or contralateral breast, or prior or concurrent malignancy other than DCIS Strategy to reduce bias: Stratification Variables: Age, margin, method of detection, architecture, necrosis, nuclear grade, and tumor size in stratification. | IV
Solin, 1993^222^ Country: USA and Europe Design: Case-series Active treatment: LR Control treatment: None | Source: 9 institutions in 4 countries in North America and Europe Number: 172 Length of followup (months): 84 Age: Median 51 (27–77) Outcomes: Combined ipsiliateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality; distant recurrence | Inclusion criteria: Women with unilateral TisN0M0, receiving breast-conserving surgery followed by definitive breast irradiation Exclusion criteria: Paget disease of nipple, prior or concurrent invasive or microinvasive carcinoma of the ipsilateral or contralateral breast, or prior or concurrent malignancy other than DCIS Strategy to reduce bias: Stratification Variables: Margin, architecture, necrosis, and nuclear grade in stratification. | IV
Stallard, 2001^223^ Country: UK Design: Case-series Active treatment: M, LR, LT, LRT, or L Control treatment: None | Source: University department of Surgery and Pathology, Glasgow, UK Number: 220 Length of followup (months): 132 Age: Median 58 (30–86) Outcomes: Ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality; regional recurrence; distant recurrence | Inclusion criteria: Women with DCIS treated at the authors’ institute Exclusion criteria: None. Strategy to reduce bias: Stratification and multivariate analysis Variables: Distance from nipple to lesion, nuclear grade, and radiation therapy in multivariate analysis. Margin, mammogram characteristics, distance from lesion to nipple, architecture, necrosis, age, modified VNPI, tamoxifen treatment, and nuclear grade in stratification. | II-2C
Szelei-Steven 2000^224^ Country: USA Design: Case-series Active treatment: M, LR, or L Control treatment: None | Source: The Tumor Registry database of the Ochsner Cancer Institute Number: 128 Length of followup (months): 104.4 Age: Median 58 (28–86) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; breast cancer mortality; distant recurrence | Inclusion criteria: Women with pure DCIS registered in the Tumor Registry database of the Ochsner Cancer Institute Exclusion criteria: Pure LCIS, microinvasive disease, or nodal involvement Strategy to reduce bias: Stratification Variables: Age, family history, method of detection, margin, and architecture in stratification. | Registry (retrospective analysis with comparison groups)
Van Zee, 1999^225^ Country: USA Design: Case-series Active treatment: LR or L Control treatment: None | Source: Memorial Sloan-Kettering Cancer Center Number: 157 Length of followup (months): 74 Age: Median 60 (20–87) Outcomes: Combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS treated by BCS with or without radiotherapy at authors’ institute Exclusion criteria: Lost followup and incomplete radiation therapy data Strategy to reduce bias: Stratification and multivariate analysis Variables: Not specified in multivariate analysis. Age, menopausal status, method of detection, tumor size, architecture, nuclear grade, margin, and radiation treatment in stratification. | II-2C
Warnberg, 2001^226^ Country: Sweden Design: Case-control Active treatment: M, LR, or L Control treatment: None | Source: Swedish Cancer Registry Number: NA Length of followup (months): NA Age: NA Outcomes: Ipsilateral invasive cancer; contralateral invasive cancer; breast cancer mortality | Inclusion criteria: Women with DCIS registered in SCR Exclusion criteria: History of earlier breast cancer, invasive cancer, diagnosed by cytology only, LCIS, benign tumors, and male Strategy to reduce bias: Multivariate analysis Variables: Age, tumor size, and treatment in multivariate analysis. | Registry (case control study with comparison groups)
Warnberg, 2002^227^ Country: Sweden Design: Case-series Active treatment: NA Control treatment: None | Source: University Hospital of Uppsala and Central Hospital of Vasteras, all cases are included in Swedish Cancer Registry Number: 180 Length of followup (months): 79 Age: NA Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality | Inclusion criteria: Women with DCIS treated at authors’ institute with complete phenotype classification. Exclusion criteria: Not enough tumor material to complete IH staining Strategy to reduce bias: Stratification Variables: Phenotype in stratification. | IV
Warnberg, 1999^228^ Country: Sweden Design: Case-series Active treatment: LR or L Control treatment: None | Source: University Hospital of Uppsala and Central Hospital of Vasteras, all cases are included in Swedish Cancer Registry Number: 195 Length of followup (months): 58 Age: NA Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; contralateral DCIS; contralateral invasive cancer; combined contralateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS treated at authors’ institute Exclusion criteria: Invasive, benign, or LCIS Strategy to reduce bias: stratification Variables: EORTC grade, VN grade, and nuclear grade in stratification. | IV
Holland, 1998^229^ Country: UK Design: Case-series Active treatment: LRT, LR, LT or L Control treatment: None | Source: University Hospital of South Manchester Number: 129 Length of followup (months): 35 Age: Median 57 (37–78) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; combined contralateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS treated at authors’ institute Exclusion criteria: None Strategy to reduce bias: Stratification Variables: Margin and modified VNPI in stratification | IV
Fowble, 1997^230^ Country: USA Design: Case-series Active treatment: LR Control treatment: None | Source: Fox Chase Cancer Center and University of Pennsylvania Number: 110 Length of followup (months): 63.6 Age: Median 56 (37–81) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; contralateral DCIS; contralateral invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality; regional recurrence; distant recurrence | Inclusion criteria: Women with mammographically detected DCIS treated by BCS and radiation at authors’ institute Exclusion criteria: Prior history of breast cancer Strategy to reduce bias: Stratification Variables: Age, family history, mammogram characteristics, race, margin, reexcision, and architecture in stratification | IV
Lara, 2003^231^ Country: USA Design: Case-series Active treatment: M, MR, L, or LR Control treatment: None | Source: Tumor registry of Saint Barnabas Medical Center, New Jersey Number: 102 Length of followup (months): 228 Age: Mean 56 (31–82) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; contralateral DCIS; contralateral invasive cancer; combined contralateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS treated by partial or total mastectomy with ALND Exclusion criteria: Previous evidence of invasive disease in ipsi or contralalteral breast, or a suspicion of microinvasive Strategy to reduce bias: None Variables: None | IV
Idvall, 2003^232^ Country: Sweden Design: Case-series Active treatment: L Control treatment: None | Source: Cancer registry of the Southern Swedish Health Care Region Number: 121 Length of followup (months): NA Age: Median 58 (30–84) Outcomes: Combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS treated by BCS alone in the registry Exclusion criteria: None Strategy to reduce bias: Stratification and multivariate analysis Variables: Polarisation, nuclear grade, mitotic frequency, and growth pattern in multivariate analysis. Polarisation, nuclear grade, and mitotic frequency in stratification. | Registry (retrospective analysis without comparison groups)
Rodrigues, 2004^233^ Country: Spain Design: Case-series Active treatment: LR Control treatment: None | Source: Institut d’Oncologia Radioterapica, Hospital de l’Esperanca, Barcelona, Spain Number: 101 Length of followup (months): 34 Age: Mean 55.8 (NA) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; breast cancer mortality; distant recurrence | Inclusion criteria: Women with DCIS treated by BCS and radiation at authors’ institute Exclusion criteria: Diffuse microcalcification on the mammograms, multicentric disease, more than 4cm in diameter, a difficult followup, and a worse correlation between tumor size/breast size Strategy to reduce bias: None Variables: None | IV
Bemitez, 2006^234^ Country: USA Design: Case-series Active treatment: L + APBI Control treatment: None | Source: 12 institutions in phase II MammoSite Breast Brachytherapy clinical study Number: 100 Length of followup (months): 9.5 Age: Mean 60.8 (NA) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS who were undergoing BCS and treated with MammoSite device to deliver APBI, age ≥45, unicentric pure DCIS, mammographic lesion of 3cm or less, negative margins 1 mm or more, post-op final gross pathologic size ≤5cm, clinical node negative, and post-op mammogram showing the absence of any residual microcalcification Exclusion criteria: The MammoSite catheter was removed due to inadequate skin distance, poor cavity conformance, positive margin, final histology, and physician decision Strategy to reduce bias: None Variables: None | Registry (retrospective analysis without comparison groups)
Douglas-Jones, 2002^235^ Country: UK Design: Case-series Active treatment: L Control treatment: None | Source: University of Wales College of Medicine, South Glamorgan, UK Number: 115 Length of followup (months): NA Age: NA (50–65) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; distant recurrence | Inclusion criteria: Women with pure screen detected DCIS, treated by BCS at authors’ institute Exclusion criteria: A completion mastectomy Strategy to reduce bias: Multivariate analysis Variables: Not specified in multivariate analysis | IV
Gilleard, 2008^236^ Country: UK Design: Case-series Active treatment: L Control treatment: None | Source: The Royal Devon and Exeter Hospital Number: 215 Length of followup (months): 53 Age: Mean 60.3 (33–91) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; breast cancer mortality | Inclusion criteria: Women with DCIS treated by BCS alone in the authors’ institute Exclusion criteria: Mastectomy, radiation therapy, or simultaneously occurring invasive disease Strategy to reduce bias: Stratification Variables: Age, margin, tumor size, re-excision, VN grade, and VNPI in stratification | IV
Omlin, 2006^237^ Country: Multi-countries Design: Case-series Active treatment: LR or L Control treatment: None | Source: The Rare Cancer Network Number: 373 Length of followup (months): 72 Age: Median 41 (23–45) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality; regional recurrence; distant recurrence | Inclusion criteria: Women with DCIS, treated by BCS, age 45 years or younger at diagnosis, from 18 institutions Exclusion criteria: None Strategy to reduce bias: Multivariate analysis Variables: Age, method of detection, tumor size, necrosis, grade, margin, ER status, and treatment in multivariate analysis | II-2C
Habel, 1998^238^ Country: USA Design: Case-series Active treatment: LR or L Control treatment: None | Source: 13 counties of western Washington in SEER Number: 709 Length of followup (months): 62 Age: NA (20–74) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality | Inclusion criteria: Women with first unilateral DCIS identified from 13 counties of western Washington in SEER, treated by BCS, and at least 6 months of followup time Exclusion criteria: LCIS, mastectomy, or previously diagnosed with DCIS or invasive breast cancer Strategy to reduce bias: Stratification and multivariate analysis Variables: Method of detection, tumor size, architecture, marital status, menarche age, parity, first birth age, family history, education, BMI, alcohol consumption, HRT, oral contraceptives or radiation treatment plus age and follow-up time in multivariate analysis. Method of detection, tumor size, architecture, age, marital status, menarche, parity, first birth age, family history, education, BMI, alcohol consumption, HRT, oral contraceptives and radiation treatment in stratification. | SEER Registry (retrospective analysis with comparison groups)
Ellsworth, 2007^239^ Country: USA Design: Case-series Active treatment: M or BCS Control treatment: None | Source: The Windber Medical Center, Memorial Medical Center Pathology Department, or Clinical Breast Care Project Pathology Laboratory Number: 100 Length of followup (months): NA Age: Average 59.7 (NA) Outcomes: Ipsilateral invasive cancer; all-cause mortality | Inclusion criteria: Pure DCIS with no evidence of an invasive component from the Windber Medical Center, Memorial Medical Center Pathology Department, or Clinical Breast Care Project Pathology Laboratory Exclusion criteria: None Strategy to reduce bias: None Variables: None | IV
Ottesen, 2000^240^ Country: Denmark Design: Case-series Active treatment: L Control treatment: None | Source: DBCG 82-IS (Danish nationwide prospective study of in situ carcinoma of the breast) Number: 168 Length of followup (months): 120 Age: Median 48 (29–85) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; contralateral DCIS; contralateral invasive cancer; combined contralateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS in the protocol DBCG 82-IS from 1982 to 1989 and treated with excision only. Exclusion criteria: Cases with microinvasion, with previous malignant disease (except in situ cervical cancer and skin cancer), or missing for histopathological review. Strategy to reduce bias: Stratification and multivariate analysis Variables: Tumor size, necrosis, and nuclear size in multivariate analysis. Tumor size, necrosis, and nuclear size, and architecture in stratification. | DBCG 82-IS Registry (retrospective analysis without comparison groups)
Kollias, 1999^241^ Country: Australia Design: Case-series Active treatment: NA Control treatment: None | Source: The Nottingham City Hospital Number: 238 Length of followup (months): 108 Age: NA Outcomes: Combined contralateral DCIS and invasive cancer | Inclusion criteria: Women with operable invasive cancer and DCIS treated at authors’ institute, and only results of DCIS cases are abstracted Exclusion criteria: Patients with synchronous bilateral breast cancer Strategy to reduce bias: None Variables: None | IV
Jha, 2001^242^ Country: UK Design: Case-series Active treatment: M, LR, or L Control treatment: None | Source: National Breast Cancer Screening Programmes Number: 292 Length of followup (months): 88 Age: Median 59 (51–65) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; distant recurrence | Inclusion criteria: Women with DCIS detected by National Breast Cancer Screening Programmes Exclusion criteria: Lost followup, invasive component, or bilateral disease Strategy to reduce bias: None Variables: None | II-2C
Rakovitch, 2007^243^ Country: Canada Design: Case-series Active treatment: LR Control treatment: L | Source: University of Toronto Number: 310 Length of followup (months): 82.8 Age: Median 56 (25–93) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS treated by BCS with or without radiotherapy at authors’ institute Exclusion criteria: Mastectomy Strategy to reduce bias: Multivariate analysis Variables: Radiation, nuclear grade, multifocality, and margin in multivariate analysis. Multifocality in stratification. | II-2C
Pinsky, 2007^244^ Country: USA Design: Case-series Active treatment: LR Control treatment: None | Source: Patients at William Beaumont Hospital, Royal Oak, or another hospital in Michigan Number: 513 Length of followup (months): NA Age: NA Outcomes: Combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS (Tis N0 M0) treated with lumpectomy followed by radiation therapy, with complete histologic review, at the authors’ institute. Exclusion criteria: Cases with invasive or microinvasive carcinoma of the breast, or incomplete pathologic review. Strategy to reduce bias: None Variables: None | IV
Carlson, 2007^245^ Country: USA Design: Case-series Active treatment: SSM Control treatment: None | Source: Emory University Hospital Number: 225 Length of followup (months): 82.3 Age: Mean 44.3 (24–63) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; regional recurrence; distant recurrence | Inclusion criteria: Women with DCIS treated by SSM and immediate reconstruction Exclusion criteria: Microinvasion Strategy to reduce bias: Stratification and multivariate analysis Variables: Not specified in multivariate analysis Age, tumor size, necrosis, grade (not specified), margin, core biopsy, and SSM type in stratification. | IV
Kricker, 2004^246^ Country: Australia Design: Case-series Active treatment: M, LR, or L Control treatment: None | Source: New South Wales Cancer Registry Number: 945 Length of followup (months): 51.6 Age: NA Outcomes: Ipsilateral invasive cancer; contralateral invasive cancer | Inclusion criteria: Women with first diagnosed DCIS in 1995–2000 and notified to the NSW Central Cancer Registry Exclusion criteria: With previous or simultaneously (same month) diagnosed of invasive breast cancer, or microinvasive disease Strategy to reduce bias: None Variables: None | Registry (retrospective analysis with comparison groups)
Temple, 1989^247^ Country: Canada Design: Case-series Active treatment: LR or L Control treatment: None | Source: Alberta Cancer Registry Number: 109 Length of followup (months): 72 Age: Mean 55 (30–88) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; breast cancer mortality; distant recurrence | Inclusion criteria: Women with DCIS or LCIS in the Alberta Cancer Registry, with or without microinvasion, reviewed by three pathologists, and only DCIS data are considered Exclusion criteria: None Strategy to reduce bias: None Variables: None | Registry (retrospective analysis with comparison groups)
Franceschi, 1998^248^ Country: Switzerland Design: Case-series Active treatment: NA Control treatment: None | Source: Vaud Cancer Registry Number: 186 Length of followup (months): NA Age: Median 55 (27–87) Outcomes: Ipsilateral invasive or contralateral invasive cancer | Inclusion criteria: Women with first DCIS or LCIS in the Vaud Cancer Registry and only DCIS data are considered Exclusion criteria: History of previous malignancies except non-melanoma skin cancer, or concurrent cancer of the breast or other sites Strategy to reduce bias: None Variables: None | Registry (retrospective analysis without comparison groups)
Li, 2006^249^ Country: USA Design: Case-series Active treatment: M, LR, or L Control treatment: None | Source: SEER Number: 37,692 Length of followup (months): NA Age: Mean 58.6 (NA) Outcomes: Ipsilateral invasive cancer; contralateral invasive cancer | Inclusion criteria: Women with unilateral DCIS or LCIS (only DCIS data are abstracted) without a previous history of any type of in situ or invasive cancer Exclusion criteria: Less than 6 months of followup Strategy to reduce bias: Multivariate analysis Variables: Age, year, registry site, and surgery/radiation in multivariate analysis. | SEER Registry (retrospective analysis with comparison groups)
Schouten van der Velden, 2006^250^ Country: Netherlands Design: Case-series Active treatment: M or L Control treatment: None | Source: Cancer registry of the Comprehensive Cancer Centre of Middle Netherlands Number: 502 Length of followup (months): 50.6 Age: Median 56.4 (26.5–89.7) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS treated through the registry Exclusion criteria: Simultaneously other malignancies except nonmelanoma skin cancer, no medical record, microinvasion, LCIS component, history of breast cancer, no followup data Strategy to reduce bias: Stratification Variables: Age, family history, method of detection, tumor size, grade (not specified), margin, reexcision, and treatment in stratification | Registry (retrospective analysis with comparison groups)
Jhingran, 2002^251^ Country: USA Design: Case-series Active treatment: LR Control treatment: None | Source: MD Anderson Cancer Center Number: 150 Length of followup (months): 63 Age: Median 53 (32–81) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality; distant recurrence | Inclusion criteria: Women with DCIS treated by BCS and radiation at authors’ institute Exclusion criteria: No prior history of breast cancer with DCIS, or microinvasion Strategy to reduce bias: Stratification Variables: Age and nuclear grade in stratification | IV
Habel, 1997^252^ Country: USA Design: Case-series Active treatment: NA Control treatment: None | Source: 13 counties of western Washington in SEER Number: 1,929 Length of followup (months): 56 Age: NA (20–84) Outcomes: Contralateral DCIS; contralateral invasive cancer; combined contralateral DCIS and invasive cancer | Inclusion criteria: Women with first unilateral pure DCIS or pure LCIS identified from 13 counties of western Washington in SEER, and at least 6 months of followup time, only DCIS data are abstracted Exclusion criteria: Mixed LCIS and DCIS, a history of breast cancer, and contralateral invasive or DCIS during the same year Strategy to reduce bias: Stratification Variables: Time since diagnosis in stratification | SEER Registry (retrospective analysis without comparison groups)
Tan, 2002^253^ Country: Singapore Design: Case-series Active treatment: Bx, L, M Control treatment: None | Source: Singapore General Hospital Number: 102 Length of followup (months): 32 Age: median 52 (28–85) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; contralateral DCIS; contralateral invasive cancer; combined contralateral DCIS and invasive cancer | Inclusion criteria: Women with pure DCIS treated at the authors’ institute. Exclusion criteria: None Strategy to reduce bias: None Variables: None | IV
Roka, 2004^254^ Country: Austria Design: Case-series Active treatment: L, LR, LT, or LRT Control treatment: None | Source: Department of General Surgery, University of Vienna, Austria Number: 132 Length of followup (months): 61.6 Age: Median 56 (32–85) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality; regional recurrence; distant recurrence | Inclusion criteria: Women with DCIS treated by BCS at authors’ institute Exclusion criteria: A history of breast or any other cancer Strategy to reduce bias: Stratification Variables: Age, tumor size, nuclear grade, margin, ER, PR, p53, her-2/neu, focality, microinvasion, radiation, and hormone therapy in stratification. | II-2C
Wilson, 2006^255^ Country: UK Design: Case-series Active treatment: NA Control treatment: None | Source: University Hospital of South Manchester Number: 139 Length of followup (months): 60 Age: Median 55 (NA) Outcomes: Combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with pure DCIS treated at the authors’ institute. Exclusion criteria: None Strategy to reduce bias: Stratification and multivariate analysis Variables: Age, margin, and nuclear grade in multivariate analysis. Age, nuclear grade, margin, ER, her2, Ki67, and c-Src in stratification. | IV
Warnberg, 2008^256^ Country: Sweden Design: Case-series Active treatment: LR, M Control treatment: None | Source: Patients from Uppsala University Hospital Number: 213 Length of followup (months): 155 Age: median 60.2 (39–84) Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women in Uppland and Vastmanland counties with primary DCIS and reported to the Swedish Cancer Registry Exclusion criteria: None Strategy to reduce bias: Stratification Variables: ER, PR, her-2 | IV
Rudloff, 2009^257^ Country: USA Design: Case-series Active treatment: LR or L Control treatment: None | Source: MSKCC, New York Number: 294 Length of followup (months): 132 Age: median 55 (26–89) Outcomes: Combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with pure DCIS treated by BCT at the authors’ institute. Exclusion criteria: Review of pathology did not confirm the presence of DCIS without invasion Strategy to reduce bias: Stratification and multivariate analysis Variables: Age, method of detection, treatment, and lobular neoplasia in multivariate analysis. ADH, lobular neoplasia, and columnar cell change in stratification. | IV
Trisal, 2004^258^ Country: USA Design: Case-series Active treatment: M or L Control treatment: None | Source: City of Hope Cancer Center Number: 171 Length of followup (months): 70 Age: median 55 (27–93) Outcomes: ipsilateral DCIS; ipsilateral invasive cancer; combined ipsiliateral DCIS and invasive cancer; contralateral DCIS; contralateral invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality | Inclusion criteria: Women with pure DCIS treated at the authors’ institute. Exclusion criteria: None Strategy to reduce bias: None Variables: None | IV
Innos, 2008^259^ Country: USA Design: case-series Active treatment: M, LR, or L Control treatment: None | Source: California Cancer Registry Number: 23,547 Length of followup (months): 55 Age: NA Outcomes: Ipsilateral DCIS; ipsilateral invasive cancer; contralateral DCIS; contralateral invasive cancer; combined contralateral DCIS and invasive cancer | Inclusion criteria: Women diagnosed between 1988–1999 with a first primary carcinoma in situ of the breast Exclusion criteria: LCIS, cases diagnosed at autopsy Strategy to reduce bias: Stratification and multivariate analysis Variables: Race, age, and period of diagnosis in multivariate analysis. Race, age, period of diagnosis, time since diagnosis of first DCIS, architecture, and radiation therapy in stratification. | Registry (retrospecti ve analysis without comparison groups)
West, 2007^260^ Country: USA Design: Case-series Active treatment: LR Control treatment: L | Source: St. Joseph Hospital, Orange, CA Number: 153 Length of followup (months): 99 Age: median 55 (NA) Outcomes: Combined ipsiliateral DCIS and invasive cancer; contralateral DCIS; contralateral invasive cancer; combined contralateral DCIS and invasive cancer; breast cancer mortality; all-cause mortality | Inclusion criteria: Women with DCIS <4cm: Group 1: a minimum clear margin 5mm or reexcision margin clear and receive RT. Group 2: a minimum clear margin10mm or reexcision margin clear, tumor size <16mm, low to intermediate nuclear grade, and not receive RT. Exclusion criteria: Receiving mastectomy (112), going elsewhere for treatment (4), and positive margin refusing reexcisiom(4). Strategy to reduce bias: None Variables: None | II-2C
de Roos, 2005^261^ Country: Netherlands Design: Case-series Active treatment: M, LR, or L Control treatment: None | Source: University of Groningen Medical Center and the Martini Hospital Number: 251 Length of followup (months): 43 Age: median 57 (NA) Outcomes: Combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women treated for DCIS from 1992 to 2003 in the aythors’ institute Exclusion criteria: None Strategy to reduce bias: Stratification and multivariate analysis Variables: Not specified in multivariate analysis, but using regression analysis by elimination of variables in a stepwise manner. Age, margin, tumor size, grade, menopause status, family history, method of detection, microcalcification, FNAC, SCNB, axillary surgery, treatment, treatment according to guidelines, and period in stratification. | IV
Cox, 1997^262^ Country: USA Design: Case-series Active treatment: L or LR Control treatment: None | Source: MCC at University of South Florida Number: 103 Length of followup (months): 57.5 Age: median 52.6 (30–82) Outcomes: ipsilateral DCIS. ipsilateral invasive cancer, combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women treated with lumpectomy at authors’ institute Exclusion criteria: Diagnosis other than DCIS, postoperative mastectomy, or contralateral breast cancer development Strategy to reduce bias: Stratification and multivariate analysis Lists of variables: Age, focality, and microinvasion in multivariate analysis. Focality and microinvasion in stratification. | IV
Ciatto, 1990^263^ Country: Italy Design: Case-series Active treatment: M, LR, or L Control treatment: None | Source: The Centro per lo Studio e la Prevenzione Oncologica of Florence Number: 156 Length of followup (months): NA Age: NA (19 <40 years, 39 40–49 years, 47 50–59 years, 51>60 years) Outcomes: combined ipsiliateral DCIS and invasive cancer, contralateral DCIS, contralateral invasive cancer, combined contralateral DCIS and invasive cancer, breast cancer mortality | Inclusion criteria: Women with DCIS treated at the authors’ institute Exclusion criteria: Axillary LN involvement or Paget’s disease Strategy to reduce bias: None Lists of variables: None | IV
Page, 1995^264^ Country: USA Design: Case-series Active treatment: BX Control treatment: None | Source: Vanderbilt, Baptist, and St. Thomas Hospitals Number: 28 Length of followup (months): NA Age: NA Outcomes: ipsilateral invasive cancer, breast cancer mortality | Inclusion criteria: Women with small, noncomedo DCIS excised by biopsy only Exclusion criteria: None Strategy to reduce bias: None Lists of variables: None | IV
Sanders, 2005^265^ Country: USA Design: Case-series Active treatment: BX Control treatment: None | Source: Vanderbilt, Baptist, and St. Thomas Hospitals Number: 28 Length of followup (months): 372 Age: NA Outcomes: ipsilateral invasive cancer, breast cancer mortality | Inclusion criteria: Women with small, noncomedo DCIS excised by biopsy only Exclusion criteria: None Strategy to reduce bias: None Lists of variables: None | IV
Metz, 1999^266^ Country: USA Design: Case-series Active treatment: MR Control treatment: None | Source: University of Pennsylvania Number: 3 Length of followup (months): 88.8 Age: median 46 (NA) Outcomes: combined ipsiliateral DCIS and invasive cancer, combined contralateral DCIS and invasive cancer, breast cancer mortality, regional recurrence, distant recurrence | Inclusion criteria: Women with DCIS treated by mastectomy + radiotherapy Exclusion criteria: None Strategy to reduce bias: None Lists of variables: None | IV
de Mascarel, 2002^267^ Country: France Design: Case-series Active treatment: NA Control treatment: None | Source: Rgional Cancer Center in Bordeaux Number: 931 Length of followup (months): 87.6 Age: median 51 (NA) Outcomes: breast cancer mortality, all-cause mortality, distant recurrence | Inclusion criteria: Women with DCIS, DCIS with microinvasion, and infiltrating ductal carcinoma with DCIS as predominant component treated at authors’ institute, only DCIS or DCIS with microinvasion data were analyzed Exclusion criteria: Previous or synchronous infiltrating carcinoma Strategy to reduce bias: None Lists of variables: None | IV
Kepple, 2006^268^ Country: USA Design: Case-series Active treatment: M, LR, LT, or L Control treatment: None | Source: University of Arkansas Number: 94 Length of followup (months): 48 Age: median 57.5 (NA) Outcomes: ipsilateral DCIS, ipsilateral invasive cancer, combined ipsiliateral DCIS and invasive cancer, contralateral DCIS, contralateral invasive cancer, combined contralateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS with complete evaluation of ER, PR, HER, and p53 Exclusion criteria: Microinvasion or lack of available tissue to perform immunohistochemistry for receptors Strategy to reduce bias: Stratification Lists of variables: ER, PR, and HER2 in stratification | IV
Bowers, 1990^269^ Country: USA Design: Case-series Active treatment: M, LR, or L Control treatment: None | Source: Wilford Hall USAF Medical Center Number: 45 Length of followup (months): NA Age: mean 55 (NA) Outcomes: breast cancer mortality, all-cause mortality | Inclusion criteria: Women with breast cancer, but only DCIS result was abstracted Exclusion criteria: None Strategy to reduce bias: None Lists of variables: None | IV
de Roos, 2007^270^ Country: Netherlands Design: Case-series Active treatment: M, LR or L Control treatment: None | Source: University of Groningen Medical Center and the Martini Hospital Number: 87 Length of followup (months): 49.8 Age: median 57.7 (36.8–77.5) Outcomes: combined ipsiliateral DCIS and invasive cancer, distant recurrence | Inclusion criteria: Women with DCIS or primary operable IDC at the authors’ institute, only DCIS data were abstracted Exclusion criteria: Lack of available tissue to perform immunohistochemistry for receptors Strategy to reduce bias: Multivariate analysis Lists of variables: surgical procedure, margin, tumor size, grade, axillary status, RT, chemotherapy, Her2/neu, and p53 in multivariate analysis. | IV
Jiveliouk, 2009^271^ Country: Israel Design: Case-series Active treatment: LR Control treatment: None | Source: Tel-Aviv Sourasky Medical Center Number: 96 Length of followup (months): 52 Age: median 58 (32–81) Outcomes: combined ipsiliateral DCIS and invasive cancer, contralateral invasive cancer, breast cancer mortality, all-cause mortality, other | Inclusion criteria: Women with mammography-detected, biopsy-proven TisN0M0, no physical examination finding suspicious for overt malignancy, unilateral disease at presentation, no multicentricity, treated by BCS plus RT, no prior or concurrent invasive or microinvasive carcinoma of the ipsilateral or contralateral breast, and no prior or concurrent malignancy other than DCIS. Exclusion criteria: Lost to followup Strategy to reduce bias: None Lists of variables: None | IV
Badve, 1998^272^ Country: USA Design: Case-control Active treatment: M or L Control treatment: None | Source: Royal Marsden Hospital Number: 123 Length of followup (months): 39 for cases and 68 for controls Age: median 52 (18–76) Outcomes: ipsilateral DCIS, ipsilateral invasive cancer, combined ipsiliateral DCIS and invasive cancer, contralateral DCIS, contralateral invasive cancer, combined contralateral DCIS and invasive cancer, all- cause mortality | Inclusion criteria: Women with DCIS without relapse within 6 months and surgery only Exclusion criteria: Subsequent invasive disease in the contralalteral breast, histological material unavailable, or receiving RT Strategy to reduce bias: Stratification Lists of variables: grade, method of detection, and architecture in stratification. | II-3
Provenzano, 2003^273^ Country: Australia Design: Case-control Active treatment: LRT, LR, LT, or L Control treatment: None | Source: Victorian Cancer Registry Number: 95 Length of followup (months): 101 Age: NA (34–88) Outcomes: combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS from Registry: cases suffered an ipsilateral recurrence occuring more than 3 months after the initial surgery, controls are matched for age, date of diagnosis Exclusion criteria: None Strategy to reduce bias: Multivariate analysis. Lists of variables: Grade and one of ER, PR, P21, P53, PS2, ERBB2, Cathepin D, BCL-2, androgen receptor, or method of detection. | II-3
Barnes, 2005^274^ Country: UK Design: Case-control Active treatment: M, LR, or L Control treatment: None | Source: University Hospital of South Manchester Number: 129 Length of followup (months): 21 for cases Age: median 55 for cases and 56 for controls (39–82) Outcomes: combined ipsiliateral DCIS and invasive cancer | Inclusion criteria: Women with DCIS: 39 cases with recurrence, 90 controls without recurrence after 5 years followup Exclusion criteria: None Strategy to reduce bias: Stratification and multivariate analysis Lists of variables: grade, Ki67, HER4, age, surgery type, margin, HER2, HER3, and ER in multivariate analysis. Grade, margin, Ki67, HER4, HER2, HER3, and ER in stratification. | II-3
Amichetti, 1999^275^ Country: Italy Design: Survey Active treatment: LR Control treatment: None | Source: 6 radiation oncology departments of north-east of Italy Number: 83 Length of followup (months): 54.5 Age: median 50 (29–88) Outcomes: Quality of life | Inclusion criteria: Women with DCIS treated by BCS plus RT without any signs of disease at authors’ institute Exclusion criteria: None Strategy to reduce bias: None Lists of variables: None | IV
Turaka Year: 2009^276^ Country: USA Design: Case-series Active treatment: LR or LRT Control treatment: None | Source: Fox Chase Cancer Center Number: 440 Length of followup (months): 81.6 Age: median 56.5 (31–91) Outcomes: ipsilateral DCIS, ipsilateral invasive cancer, combined ipsiliateral DCIS and invasive cancer, combined contralateral DCIS and invasive cancer, breast cancer mortality, all-cause mortality, regional recurrence, distant metastasis | Inclusion criteria: Women with DCIS (stage 0) treated with BCS +RT at authors’ institute Exclusion criteria: Male, microinvasion, a diagnosis of Paget’s disease, mastectomy, or BCS without RT Strategy to reduce bias: stratification Lists of variables: Age. Margin, tamoxifen treatment, post-biopsy mammogram, and mammographic characteristics in stratification | IV
Kinne, 1989^277^ Country: USA Design: Case-series Active treatment: M Control treatment: None | Source: MSKCC Number: 101 Length of followup (months): 138 Age: NA Outcomes: ipsilateral DCIS, ipsilateral invasive cancer, breast cancer mortality, all-cause mortality | Inclusion criteria: Women with pure DCIS, LCIS, or mixed treated at authors’ institute. Only DCIS and mixed DCIS-LCIS were abstracted. Exclusion criteria: Previous carcinoma, bilateral breast cancer, and evidence of microinvasion Strategy to reduce bias: None Lists of variables: None | IV
Ward Year: 1992^278^ Country: USA Design: Case-series Active treatment: M or LR Control treatment: None | Source: Connecticut Tumor Registry Number: 220 Length of followup (months): NA Age: mean 58.8 (NA) Outcomes: combined ipsiliateral DCIS and invasive cancer, breast cancer mortality, all-cause mortality, other | Inclusion criteria: Either DCIS or LCIS at the CTR, but only DCIS results are abstracted Exclusion criteria: None Strategy to reduce bias: None Lists of variables: None | IV
Rosner, 1980^279^ Country: USA Design: Case-series Active treatment: M or L (LR?) Control treatment: None | Source: National breast cancer survey Number: 202 Length of followup (months): NA Age: mean 54.3 (NA) Outcomes: combined ipsiliateral DCIS and invasive cancer, other | Inclusion criteria: Collected from 498 hospitals, only DCIS data were abstracted Exclusion criteria: Nodal positive DCIS Strategy to reduce bias: stratification Lists of variables: Race in stratification. | IV
Nekhlyudov, 2006^49^ Country: USA Design: Case control Active treatment: M, L, R, T Control treatment: None | Source: Two Nurses’ Health Study cohorts Number: 114,728 Length of followup (months): NA Age: mean 52.4 in case group,47.8 in control group (NA) Outcomes: Quality of life | Inclusion criteria: Women with DCIS diagnosed between 1992 and 2000 in two NHS cohorts. Exclusion criteria: Women without completing the pre-DCIS survey, with DCIS, invasive breast cancer, or other cancer except nonmelanoma skin cancer before the initial survey, with the presence of lobular and/or invasive characteristics, missing information, receiving chemotherapy, or died before completing the followup assessment. Strategy to reduce bias: multivariate adjustment Lists of variables: age, baseline score, BMI, comobidity, menopausal status, diagnosis period, surgery, tamoxifen, and radiation therapy in multivariate analysis. | II-3
Silverstein, 2008^280^ Country: USA Design: Case control Active treatment: LR or L Control treatment: None | Source: The Breast Center in Van Nuys, California Number: 1,363 Length of followup (months): 87 Age: NA Outcomes: ipsilateral DCIS, ipsilateral invasive cancer, combined ipsiliateral DCIS and invasive cancer, breast cancer mortality, all-cause mortality, distant recurrence | Inclusion criteria: Women with pure DCIS treated at the authors’ institute. Exclusion criteria: Microinvasion. Strategy to reduce bias: None Lists of variables: None | II-2C

Table F27 Total all mortality

Author | Number of Participants | Followup Duration | Rate (or Probability) of Events
All cause mortality
Jhingran, 2002^251^ | 150 | 120 | 0.06
Vicini, 2001^180^ | 148 | 120 | 0.046
Vargas, 2005^181^ | 410 | 120 | 0.109
Vargas, 2005^181^ | 43 | 120 | 0
Vargas, 2005^181^ | 367 | 120 | 0.114
Vargas, 2005^181^ | 313 | 120 | 0.088
Vargas, 2005^181^ | 298 | 120 | 0.082
Kestin, 2000^171^ | 132 | 120 | 0.034
Kestin, 2000^171^ | 146 | 120 | 0.031
Kestin, 2000^171^ | 31 | 120 | 0.416
Kestin, 2000^171^ | 177 | 120 | 0.092
Fowble, 1997^230^ | 110 | 120 | 0.06
Di Saverio, 2008^212^ | 259 | 120 | 0.013
Di Saverio, 2008^212^ | 259 | 120 | 0.013
Ciatto, 1990^214^ | 350 | 120 | 0.04
Tunon-de-Lara, 2001^155^ | 208 | 120 | 0.00028
Amichetti, 1999^217^ | 112 | 120 | 0.012
Amichetti, 1997^199^ | 139 | 120 | 0.07
Lee, 2006^210^ | 1236 | 144 | 0.1
Lee, 2006^210^ | 430 | 144 | 0.1
Lee, 2006^210^ | 806 | 144 | 0.1
Lee, 2006^210^ | 310 | 144 | 0.11
Lee, 2006^210^ | 496 | 144 | 0.11
Ben-David, 2007^206^ | 198 | 180 | 0.252
Omlin, 2006^237^ | 373 | 120 | 0.03 (0; 0.05)
Ben-David, 2007^206^ | 198 | 120 | 0.178 (0.111; 0.274)
Vapiwala, 2006^219^ | 192 | 120 | 0.13 (0.08; 0.23)
Solin, 1996^221^ | 270 | 120 | 0.06 (0.03; 0.09)
Vapiwala, 2006^219^ | 192 | 180 | 0.29 (0.18; 0.44)
Solin, 1996^221^ | 270 | 180 | 0.13 (0.07; 0.19)
Ben-David, 2007^206^ | 198 | 60 | 0.02 (0.006, 0.06)
Vapiwala, 2006^219^ | 192 | 60 | 0.03 (0.01; 0.07)
Solin, 1996^221^ | 270 | 60 | 0.02 (0,; 0.03)
Vicini, 2008^175^ | 195 | 24 | 0.013
Jhingran, 2002^251^ | 150 | 60 | 0.03
Ciatto, 1990^214^ | 350 | 180 | 0.04
Vicini, 2001^180^ | 148 | 60 | 0.037
Vargas, 2005^181^ | 410 | 60 | 0.053
Vargas, 2005^181^ | 43 | 60 | 0
Vargas, 2005^181^ | 367 | 60 | 0.055
Vargas, 2005^181^ | 54 | 60 | 0.189
Vargas, 2005^181^ | 313 | 60 | 0.042
Vargas, 2005^181^ | 298 | 60 | 0.044
Kestin, 2000^171^ | 132 | 60 | 0.024
Kestin, 2000^208^ | 146 | 60 | 0.022
Kestin, 2000^208^ | 31 | 60 | 0.143
Kestin, 2000^208^ | 177 | 60 | 0.042
Fowble, 1997^230^ | 110 | 60 | 0.04
Ciatto, 1990^214^ | 350 | 60 | 0.02
Amichetti, 1997^199^ | 139 | 60 | 0.02
Vargas, 2005^181^ | 54 | 96 | 0.255
Meijnen, 2008^211^ | 91 | 96 | 0.043
Meijnen, 2008^211^ | 119 | 96 | 0.031
Meijnen, 2008^211^ | 210 | 96 | 0.039
Meijnen, 2008^211^ | 294 | 96 | 0.006
MacDonald, 2005^191^ | 448 | 57 | 0.054 (0.036,; 0.079)
Amichetti, 1999^217^ | 112 | 68 | 0.009 (0.001; 0.061)
Stallard, 2001^223^ | 220 | 132 | 0.032 (0.015; 0.065)
Warnberg, 2002^227^ | 180 | 79 | 0.094 (0.06; 0.147)
Omlin, 2006^237^ | 373 | 72 | 0.019 (0.009; 0.039)
Habel, 1998^238^ | 709 | 62 | 0.065 (0.049; 0.086)
Ellsworth, 2007^239^ | 100 | NA | 0.005 (0; 0.074)
Ellsworth, 2007^239^ | 29 | NA | 0.017 (0.001; 0.217)
Ellsworth, 2007^239^ | 71 | NA | 0.007 (0; 0.101)
Trisal, 2004^258^ | 171 | 70 | 0.041(0.02, 0.083)
West, 2007^260^ | 153 | 98.4 | 0.098(0.06, 0.156)
de Mascarel, 2002^267^ | 722 | 120 | 0.035
Bowers, 1990^269^ | 45 | NA | 0.067(0.022, 0.187)
Jiveliouk, 2009^271^ | 96 | 96 | 0
Bellamy, 1993^281^ | 130 | 60 | 0.077(0.042, 0.137)
Turaka, 2009^276^ | 440 | 180 | 0.08
Kinne, 1989,2535929 | 101 | 138 | 0.059(0.027, 0.126)
Roka, 2004^254^ | 132 | 61.6 | 0.152 (0.1; 0.223)
Meijnen, 2008^211^ | 91 | 80.4 | 0.044 (0.017; 0.111)
Meijnen, 2008^211^ | 119 | 80.4 | 0.034 (0.013; 0.086)
Meijnen, 2008^211^ | 210 | 80.4 | 0.038 (0.019; 0.074)
Meijnen, 2008^211^ | 294 | 80.4 | 0.017 (0.007; 0.04)

Table F28 Total breast cancer mortality

Author | Number of Participants | Followup Duration | Rate (or Probability) of Events
Breast cancer mortality
Jhingran, 2002^251^ | 150 | 120 | 0
Kestin, 2000^171^ | 132 | 120 | 0.01
Vicini, 2001^180^ | 148 | 120 | 0.009
Vargas, 2005^181^ | 410 | 120 | 0.019
Vargas, 2005^181^ | 43 | 120 | 0
Vargas, 2005^181^ | 367 | 120 | 0.02
Vargas, 2005^181^ | 313 | 120 | 0.012
Vargas, 2005^181^ | 298 | 120 | 0.012
Kestin, 2000^208^ | 146 | 120 | 0.009
Kestin, 2000^208^ | 31 | 120 | 0
Kestin, 2000^208^ | 177 | 120 | 0.008
Fowble, 1997^230^ | 110 | 120 | 0
Amichetti, 1997^199^ | 139 | 120 | 0
Silverstein, 1995^196^ | 167 | 120 | 0
Silverstein, 1995^196^ | 133 | 120 | 0.03
Lee, 2006^210^ | 1236 | 144 | 0.01
Lee, 2006^210^ | 430 | 144 | 0.008
Lee, 2006^210^ | 806 | 144 | 0.01
Lee, 2006^210^ | 310 | 144 | 0.02
Lee, 2006^210^ | 496 | 144 | 0.004
Nakamura, 2002^193^ | 260 | 144 | 0.022
Habel, 1998^238^ | 709 | 120 | 0.06 (0.01, 0.1)
Ben-David, 2007^206^ | 198 | 120 | 0.041 (0, 0.085)
Vapiwala, 2006^219^ | 192 | 120 | 0.01 (0, 0.07)
Solin, 1996^221^ | 270 | 120 | 0.03 (0.01, 0.05)
Ben-David, 2007^206^ | 198 | 180 | 0.066 (0, 0)
Vapiwala, 2006^219^ | 192 | 180 | 0.04 (0.01, 0.16)
Solin, 1996^221^ | 270 | 180 | 0.04 (0.01, 0.07)
Habel, 1998^238^ | 709 | 60 | 0.006 (0, 0.01)
Solin, 1996^221^ | 270 | 60 | 0.01 (0, 0.02)
Vicini, 2008^175^ | 195 | 24 | 0.006
Jhingran, 2002^251^ | 150 | 60 | 0
Kestin, 2000^171^ | 132 | 60 | 0
Vicini, 2001^180^ | 148 | 60 | 0
Vargas, 2005^181^ | 410 | 60 | 0.006
Vargas, 2005^181^ | 43 | 60 | 0
Vargas, 2005^181^ | 367 | 60 | 0.007
Vargas, 2005^181^ | 54 | 60 | 0.061
Vargas, 2005^181^ | 313 | 60 | 0.007
Vargas, 2005^181^ | 298 | 60 | 0.007
Kestin, 2000^208^ | 146 | 60 | 0
Kestin, 2000^208^ | 31 | 60 | 0
Kestin, 2000^208^ | 177 | 60 | 0
Ben-David, 2007^206^ | 198 | 60 | 0
Fowble, 1997^230^ | 110 | 60 | 0
Vapiwala, 2006^219^ | 192 | 60 | 0
Amichetti, 1997^199^ | 139 | 60 | 0
Chuwa, 2008^200^ | 60 | 60 | 0
Vargas, 2005^181^ | 54 | 96 | 0.063
Meijnen, 2008^211^ | 91 | 96 | 0.032
Meijnen, 2008^211^ | 119 | 96 | 0.02
Meijnen, 2008^211^ | 210 | 96 | 0.027
Meijnen, 2008^211^ | 294 | 96 | 0.006
Silverstein, 1996^194^ | 333 | 96 | 0.02
Tunon-de-Lara, 2001^155^ | 208 | 86 | 0.014 (0.005, 0.044)
Silverstein, 2003^162^ | 280 | 81 | 0.018 (0.007, 0.042)
Kestin, 2000^171^ | 132 | 84 | 0.008 (0.001, 0.052)
Nakamura, 2002^193^ | 260 | 105 | 0.019 (0.008, 0.045)
Silverstein, 1996^194^ | 138 | 79 | 0.022 (0.007, 0.065)
Silverstein, 1996^194^ | 195 | 79 | 0.003 (0, 0.039)
Silverstein, 1995^195^ | 187 | 78 | 0.003 (0, 0.041)
Silverstein, 1995^195^ | 238 | 78 | 0.008 (0.002, 0.033)
Silverstein, 1991^198^ | 109 | 51 | 0.009 (0.001, 0.062)
Silverstein, 1991^198^ | 104 | 51 | 0.01 (0.001, 0.065)
Amichetti, 1997^199^ | 139 | 81 | 0.004 (0, 0.054)
Mirza, 2000^201^ | 109 | 132 in DCIS, 144 in DCIS with microinvasion | 0.018 (0.005, 0.07)
Chagpar, 2003^202^ | 109 | 11.4 | 0.005 (0, 0.068)
Adepoju, 2006^204^ | 310 | 103.2 | 0.016 (0.007, 0.038)
Takeda, 2001^205^ | 114 | 46.7 | 0.004 (0, 0.066)
Ben-David, 2007^206^ | 198 | 74.4 | 0.02 (0.008, 0.053)
Kestin, 2000^208^ | 146 | 84 | 0.007 (0.001, 0.047)
Lee, 2006^210^ | 1236 | 72 | 0.006 (0.003, 0.013)
Lee, 2006^210^ | 430 | 72 | 0.002 (0, 0.016)
Lee, 2006^210^ | 806 | 72 | 0.009 (0.004, 0.018)
Lee, 2006^210^ | 310 | 72 | 0.019 (0.009, 0.042)
Lee, 2006^210^ | 496 | 72 | 0.002 (0, 0.014)
Meijnen, 2008^211^ | 91 | 80.4 | 0.033 (0.011, 0.097)
Meijnen, 2008^211^ | 119 | 80.4 | 0.025 (0.008, 0.075)
Meijnen, 2008^211^ | 210 | 80.4 | 0.029 (0.013, 0.062)
Meijnen, 2008^211^ | 294 | 80.4 | 0.007 (0.002, 0.027)
Ciatto, 1990^214^ | 350 | 66 | 0.02 (0.01, 0.041)
Amichetti, 1999^217^ | 112 | 68 | 0.004 (0, 0.067)
Dimpfl, 1996^218^ | 37 | 78.4 | 0.013 (0.001, 0.178)
Dimpfl, 1996^218^ | 78 | 78.4 | 0.006 (0, 0.093)
Dimpfl, 1996^218^ | 46 | 78.4 | 0.011 (0.001, 0.149)
Stallard, 2001^223^ | 220 | 132 | 0.005 (0.001, 0.032)
Szelei-Stevens, 2000^224^ | 128 | 104.4 | 0.016 (0.004, 0.06)
Szelei-Stevens, 2000^224^ | 43 | 104.4 | 0.047 (0.012, 0.168)
Warnberg, 2002^227^ | 180 | 79 | 0.011 (0.003, 0.043)
Rodrigues, 2004^233^ | 101 | 34 | 0.005 (0, 0.073)
Gilleard, 2008^236^ | 215 | 53 | 0.009 (0.002, 0.036)
Omlin, 2006^237^ | 373 | 72 | 0.013 (0.006, 0.032)
Habel, 1998^238^ | 709 | 62 | 0.016 (0.009, 0.028)
WarreL, 2005^164^ | 477 | 91 | 0.004 (0.001, 0.017)
Silverstein, 2003^190^ | 259 | 88 | 0.019 (0.008, 0.046)
MacDonald, 2005^191^ | 447 | 57 | 0.002 (0, 0.016)
Roka, 2004^254^ | 132 | 61.6 | 0.023 (0.007, 0.068)
Trisal, 2004^258^ | 171 | 70 | 0.012 (0.003, 0.046)
West, 2007^260^ | 153 | 98.4 | 0.003 (0, 0.05)
Ciatto, 1990^263^ | 156 | NA | 0.032 (0.013, 0.075)
Page, 1995^264^ | 28 | NA | 0.179 (0.076, 0.364)
Sanders, 2005^265^ | 28 | 372 | 0.179 (0.076, 0.364)
Metz, 1999,^266^ | 3 | 88.8 | 0.125 (0.007, 0.734)
de Mascarel I, 2002^267^ | 722 | 87.6 | 0.01 (0.005, 0.02)
Bowers, 1990^269^ | 45 | NA | 0.011 (0.001, 0.151)
Jiveliouk, 2009^271^ | 96 | 96 | 0
Turaka, 2009^276^ | 440 | 180 | 0.07
Kinne, 1989^277^ | 101 | 138 | 0.01 (0.001, 0.067)
Ward, 1992^278^ | 178 | 120 | 0.011 (0.003, 0.044)
Warren, 2005^164^ | 477 | 91 | 0.008 (0.003, 0.022)

Table F29 Total distant metastasis

Author | Number of Participants | Followup Duration | Rate (or Probability) of Events
Distant Metastasis
Kricker, 2004^246^ | 945 | 51.6 | 0.044 (0.033, 0.06)
Franceschi, 1998^248^ | 168 | NA | 0.119 (0.078, 0.177)
Li, 2006^249^ | 37692 | NA | 0.04 (0.038, 0.042)
Kricker, 2004^246^ | 945 | 51.6 | 0.002 (0.001, 0.008)
Warnberg, 2002^227^ | 180 | 79 | 0.194 (0.143, 0.259)
Warnberg, 2002^227^ | 180 | 79 | 0.128 (0.086, 0.185)
Warnberg, 2002^227^ | 180 | 79 | 0.067 (0.038, 0.114)
Silverstein, 2003^190^ | 259 | 88 | 0.023 (0.01, 0.051)
MacDonald, 2005^191^ | 446 | 57 | 0.002 (0, 0.016)
Nakamura, 2002^193^ | 260 | 105 | 0.023 (0.01, 0.05)
Vargas, 2005^181^ | 410 | 120 | 0.014
Vargas, 2005^181^ | 43 | 120 | 0
Vargas, 2005^181^ | 367 | 120 | 0.015
Vargas, 2005^181^ | 313 | 120 | 0.012
Vargas, 2005^181^ | 298 | 120 | 0.012
Lee, 2006^210^ | 1236 | 144 | 0.01
Lee, 2006^210^ | 430 | 144 | 0.008
Lee, 2006^210^ | 806 | 144 | 0.015
Lee, 2006^210^ | 310 | 144 | 0.02
Lee, 2006^210^ | 496 | 144 | 0.004
Vicini, 2008^175^ | 195 | 24 | 0.006
Vargas, 2005^181^ | 410 | 60 | 0.01
Vargas, 2005^181^ | 43 | 60 | 0
Vargas, 2005^181^ | 367 | 60 | 0.01
Vargas, 2005^181^ | 54 | 60 | 0.063
Vargas, 2005^181^ | 313 | 60 | 0.007
Vargas, 2005^181^ | 298 | 60 | 0.007
Bonnier, 1999^154^ | 46 | 60 | 0.01 (0, 0.02)
Bonnier, 1999^154^ | 120 | 60 | 0.03 (0.02, 0.04)
Bonnier, 1999^154^ | 21 | 84 | 0.01 (0, 0.02)
Bonnier, 1999^154^ | 50 | 84 | 0.06 (0.04, 0.08)
Vargas, 2005^181^ | 54 | 96 | 0.063
Meijnen, 2008^211^ | 91 | 96 | 0.043
Meijnen, 2008^211^ | 119 | 96 | 0.042
Meijnen, 2008^211^ | 210 | 96 | 0.04
Meijnen, 2008^211^ | 294 | 96 | 0.009
Tunon-de-Lara, 2001^155^ | 208 | 86 | 0.005 (0.001, 0.033)
Cutuli, 2001^160^ | 716 | 91 | 0.02 (0.012, 0.033)
Cutuli, 2001^160^ | 145 | 91 | 0.014 (0.003, 0.053)
Cutuli, 2001^160^ | 145 | 91 | 0.014 (0.003, 0.053)
Cutuli, 2001^160^ | 435 | 91 | 0.014 (0.006, 0.03)
Silverstein, 2003^162^ | 280 | 81 | 0.025 (0.012, 0.051)
Vicini, 2008^175^ | 195 | 28.6 | 0.005 (0.001, 0.035)
Fish, 1998^183^ | 124 | 60 | 0.004 (0, 0.061)
Cutuli, 2002^188^ | 515 | 84 | 0.014 (0.006, 0.028)
Silverstein, 1996^194^ | 138 | 79 | 0.029 (0.011, 0.075)
Silverstein MJ, 1996^194^ | 195 | 79 | 0.003 (0, 0.039)
Silverstein, 1995^195^ | 187 | 78 | 0.011 (0.003, 0.042)
Silverstein, 1995^195^ | 238 | 78 | 0.013 (0.004, 0.038)
Silverstein, 1991^198^ | 109 | 51 | 0.018 (0.005, 0.07)
Amichetti, 1997^199^ | 139 | 81 | 0.004 (0, 0.054)
Chuwa, 2008^200^ | 67 | 86 | 0.007 (0, 0.107)
Chuwa, 2008^200^ | 103 | 86 | 0.005 (0, 0.072)
Mirza, 2000^201^ | 109 | 132 in DCIS, 144 in DCIS with microinvasion | 0.018 (0.005, 0.07)
Chagpar, 2003^202^ | 109 | 11.4 | 0.005 (0, 0.068)
Ben-David, 2007^206^ | 198 | 74.4 | 0.01 (0.003, 0.039)
Asjoe, 2007^207^ | 32 | 36 | 0.031 (0.004, 0.191)
Lee, 2006^210^ | 1236 | 72 | 0.008 (0.004, 0.015)
Lee, 2006^210^ | 430 | 72 | 0.005 (0.001, 0.018)
Lee, 2006^210^ | 806 | 72 | 0.01 (0.005, 0.02)
Lee, 2006^210^ | 310 | 72 | 0.023 (0.011, 0.047)
Lee, 2006^210^ | 496 | 72 | 0.002 (0, 0.014)
Meijnen, 2008^211^ | 91 | 80.4 | 0.044 (0.017, 0.111)
Meijnen, 2008^211^ | 119 | 80.4 | 0.025 (0.008, 0.075)
Meijnen, 2008^211^ | 210 | 80.4 | 0.033 (0.016, 0.068)
Meijnen, 2008^211^ | 294 | 80.4 | 0.007 (0.002, 0.027)
Dimpfl, 1996^218^ | 37 | 78.4 | 0.013 (0.001, 0.178)
Dimpfl, 1996^218^ | 78 | 78.4 | 0.006 (0, 0.093)
Dimpfl, 1996^218^ | 46 | 78.4 | 0.011 (0.001, 0.149)
Vapiwala, 2006,^219^ | 192 | 74.4 | 0.01 (0.003, 0.041)
Solin, 1996^221^ | 270 | 123.6 | 0.03 (0.015, 0.058)
Stallard, 2001^223^ | 153 | 132 | 0.007 (0.001, 0.045)
Szelei-Stevens, 2000^224^ | 43 | 104.4 | 0.047 (0.012, 0.168)
Fowble, 1997^230^ | 110 | 63.6 | 0.009 (0.001, 0.062)
Rodrigues, 2004^233^ | 101 | 34 | 0.005 (0, 0.073)
Douglas-Jones, 2002^235^ | 115 | NA | 0.009 (0.001, 0.059)
Omlin, 2006^237^ | 373 | 72 | 0.016 (0.007, 0.035)
Jha, 2001^242^ | 124 | 88 | 0.008 (0.001, 0.055)
Carlson, 2007^245^ | 223 | 82.3 | 0.009 (0.002, 0.035)
Temple, 1989^247^ | 109 | 72 | 0.018 (0.005, 0.07)
Jhingran, 2002^251^ | 150 | 63 | 0.003 (0, 0.051)
Roka, 2004^254^ | 132 | 61.6 | 0.015 (0.004, 0.059)
Metz, 1999^266^ | 3 | 88.8 | 0.125 (0.007, 0.734)
de Mascarel, 2002^267^ | 722 | 120 | 0.02
de Roos, 2007^270^ | 87 | 49.8 | 0.011 (0.002, 0.077)
Turaka, 2009^276^ | 440 | 81.6 | 0.023 (0.012, 0.042)
Silverstein, 2008^280^ | 334 | 111 | 0.021 (0.01, 0.043)
Silverstein, 2008^280^ | 562 | 76 | 0.002 (0, 0.013)
Silverstein, 2008^280^ | 467 | 85 | 0.004 (0.001, 0.017)
Solin, 1996^221^ | 270 | 60 | 0.01 (0, 0.02)
Solin, 1996^221^ | 270 | 120 | 0.03 (0.01, 0.05)
Solin, 1996^221^ | 270 | 180 | 0.04 (0.01, 0.06)

Table F30 Total regional recurrence

Author | Number of Participants | Followup Duration | Rate (or Probability) of Events
Regional Recurrence
Cutuli, 2001^160^ | 716 | 91 | 0.018 (0.011, 0.031)
Cutuli, 2001^160^ | 145 | 91 | 0.003 (0, 0.052)
Cutuli, 2001^160^ | 145 | 91 | 0.003 (0, 0.052)
Cutuli, 2001^160^ | 435 | 91 | 0.018 (0.009, 0.036)
Fish, 1998^183^ | 18 | 60 | 0.056 (0.008, 0.307)
Fowble, 1997^230^ | 110 | 63.6 | 0.005 (0, 0.068)
Omlin, 2006^237^ | 373 | 72 | 0.021 (0.011, 0.042)
Vapiwala, 2006^219^ | 192 | 74.4 | 0.003 (0, 0.04)
Stallard, 2001^223^ | 67 | 132 | 0.03 (0.007, 0.112)
Carlson, 2007^245^ | 223 | 82.3 | 0.009 (0.002, 0.035)
Roka, 2004^254^ | 132 | 61.6 | 0.015 (0.004, 0.059)
Cutuli, 2002^188^ | 515 | 84 | 0.017 (0.009, 0.033)
Vicini, 2008^175^ | 195 | 28.6 | 0.005 (0.001, 0.035)
Amichetti, 1997^199^ | 139 | 81 | 0.007 (0.001, 0.049)
Asjoe, 2007^207^ | 32 | 36 | 0.031 (0.004, 0.191)
Asjoe, 2007^207^ | 104 | 36 | 0.029 (0.009, 0.086)
Metz, 1999^266^ | 3 | 88.8 | 0.125 (0.007, 0.734)
Turaka, 2009^276^ | 440 | 81.6 | 0.005 (0.001, 0.018)
Tunon-de-Lara, 2001^155^ | 208 | 86 | 0.01 (0.002, 0.038)

Table F31 Total local DCIS or Invasive

Author | Number of Participants | Followup Duration | Rate (or Probability) of Events
Local DCIS or invasive recurrence
Habel, 1998^238^ | 709 | 120 | 0.31 (0.24, 0.38)
Ben-David, 2007^206^ | 198 | 120 | 0.098 (0.052, 0.144)
Vapiwala, 2006^219^ | 192 | 120 | 0.1 (0.05, 0.2)
Solin, 1996^221^ | 270 | 120 | 0.16 (0.11, 0.21)
Omlin, 2006^237^ | 57 | 120 | 0.54 (0.33, 0.76)
Omlin, 2006^237^ | 166 | 120 | 0.28 (0.17, 0.39)
Omlin, 2006^237^ | 150 | 120 | 0.14 (0.07, 0.22)
Cutuli, 2002^188^ | 515 | 120 | 0.182 (0.133, 0.23)
Cutuli, 2002^188^ | 190 | 120 | 0.438 (0.3, 0.577)
Vapiwala, 2006^219^ | 192 | 180 | 0.15 (0.08, 0.26)
Solin, 1996^221^ | 270 | 180 | 0.19 (0.13, 0.25)
Habel, 1998^238^ | 709 | 60 | 0.15 (0.12, 0.18)
Ben-David, 2007^206^ | 198 | 60 | 0.059 (0.026, 0.093)
Vapiwala, 2006^219^ | 192 | 60 | 0.03 (0.01, 0.07)
Solin, 1996^221^ | 270 | 60 | 0.07 (0.04, 0.1)
Cutuli, 2002^188^ | 515 | 84 | 0.126 (0.094, 0.158)
Cutuli, 2002^188^ | 190 | 84 | 0.324 (0.25, 0.397)
Jhingran, 2002^251^ | 150 | 120 | 0.12
Jhingran, 2002^251^ | 150 | 120 | 0.06
Jhingran, 2002^251^ | 150 | 120 | 0.03
Rakovitch, 2007^243^ | 310 | 120 | 0.28
Rakovitch, 2007^243^ | 305 | 120 | 0.18
Kestin, 2000^171^ | 132 | 120 | 0.103
Vicini, 2001^180^ | 148 | 120 | 0.124
Vargas, 2005^181^ | 410 | 120 | 0.107
Vargas, 2005^181^ | 43 | 120 | 0.095
Vargas, 2005^181^ | 367 | 120 | 0.105
Vargas, 2005^181^ | 313 | 120 | 0.094
Vargas, 2005^181^ | 298 | 120 | 0.095
Kestin, 2000^208^ | 146 | 120 | 0.092
Kestin, 2000^208^ | 31 | 120 | 0.078
Kestin, 2000^208^ | 177 | 120 | 0.091
Adepoju, 2006^204^ | 211 | 120 | 0.084
Adepoju, 2006^204^ | 92 | 120 | 0.295
Amichetti, 1999^217^ | 112 | 120 | 0.09
Fowble, 1997^230^ | 110 | 120 | 0.15
Silverstein, 1995^196^ | 167 | 120 | 0.02
Silverstein, 1995^196^ | 133 | 120 | 0.19
Amichetti, 1997^199^ | 139 | 120 | 0.14
MacDonald, 2006^192^ | 212 | 144 | 0.139
MacDonald, 2006^192^ | 60 | 144 | 0.025
Lee, 2006^210^ | 1236 | 144 | 0.19
Lee, 2006^210^ | 430 | 144 | 0.01
Lee, 2006^210^ | 806 | 144 | 0.28
Lee, 2006^210^ | 310 | 144 | 0.24
Lee, 2006^210^ | 496 | 144 | 0.31
Nakamura, 2002^193^ | 260 | 144 | 0.24
Ben-David, 2007^206^ | 198 | 180 | 0.125
Vicini, 2008^175^ | 195 | 24 | 0
Schouten van der Velden, 2006^250^ | 502 | 48 | 0.134
Schouten van der Velden, 2006^250^ | 329 | 48 | 0.169
Schouten van der Velden, 2006^250^ | 173 | 48 | 0.067
Jhingran, 2002^251^ | 150 | 60 | 0.04
Ringberg, 2000^186^ | 119 | 60 | 0.04
Ringberg, 2000^186^ | 66 | 60 | 0.06
Ringberg, 2000^186^ | 121 | 60 | 0.21
Schouten van der Velden, 2007^163^ | 408 | 60 | 0.013
Schouten van der Velden, 2007^163^ | 153 | 60 | 0.094
Schouten van der Velden, 2007^163^ | 237 | 60 | 0.249
Jhingran, 2002^251^ | 150 | 60 | 0.03
Rakovitch, 2007^243^ | 310 | 60 | 0.15
Rakovitch, 2007^243^ | 305 | 60 | 0.07
Kestin, 2000^171^ | 132 | 60 | 0.089
Vicini, 2001^180^ | 148 | 60 | 0.102
Vargas, 2005^181^ | 410 | 60 | 0.071
Vargas, 2005^181^ | 43 | 60 | 0.095
Vargas, 2005^181^ | 367 | 60 | 0.069
Vargas, 2005^181^ | 54 | 60 | 0.13
Vargas, 2005^181^ | 313 | 60 | 0.06
Vargas, 2005^181^ | 298 | 60 | 0.061
Kestin, 2000^208^ | 146 | 60 | 0.08
Kestin, 2000^208^ | 31 | 60 | 0.078
Kestin, 2000^208^ | 177 | 60 | 0.08
Takeda, 2001^205^ | 48 | 60 | 0.06
Takeda, 2001^205^ | 66 | 60 | 0.189
Amichetti, 1999^217^ | 112 | 60 | 0.07
Fowble, 1997^230^ | 110 | 60 | 0.01
Fowble, 1997^230^ | 110 | 60 | 0.01
Rodrigues, 2004^233^ | 101 | 60 | 0.064
Amichetti, 1997^233^ | 139 | 60 | 0.07
Chuwa, 2008^200^ | 60 | 60 | 0.058
Vargas, 2005^181^ | 54 | 96 | 0.419
Meijne, 2008^211^ | 91 | 96 | 0.156
Meijne, 2008^211^ | 119 | 96 | 0.088
Meijne, 2008^211^ | 210 | 96 | 0.12
Meijne, 2008^211^ | 294 | 96 | 0.009
Gilleard, 2008^236^ | 215 | 96 | 0.17
Silverstein, 1996^194^ | 333 | 96 | 0.2
Ciatto, 1990^214^ | 37 | 66 | 0.011
Ciatto, 1990^214^ | 103 | 66 | 0.014
Ciatto, 1990^214^ | 210 | 66 | 0.002
Roka, 2004^254^ | 33 | 61.6 | 0.051
Roka, 2004^254^ | 99 | 61.6 | 0.121
Li, 2006^249^ | 37692 | NA | 0.054
Vicini, 2001^180^ | 148 | 86.4 | 0.115 (0.073, 0.177)
Warren, 2005^164^ | 477 | 91 | 0.107 (0.082, 0.138)
Chan, 2001^159^ | 129 | 47 | 0.186 (0.128, 0.263)
Chan, 2001^159^ | 18 | 47 | 0.111 (0.028, 0.352)
Chan, 2001^159^ | 49 | 47 | 0.102 (0.043, 0.223)
Chan, 2001^159^ | 9 | 47 | 0.111 (0.015, 0.5)
Chan, 2001^159^ | 18 | 47 | 0.111 (0.028, 0.352)
Chan, 2001^159^ | 9 | 47 | 0.111 (0.015, 0.5)
Chan, 2001^159^ | 9 | 47 | 0.111 (0.015, 0.5)
Cutuli, 2001^160^ | 716 | 91 | 0.145 (0.121, 0.173)
Cutuli, 2001^160^ | 145 | 91 | 0.021 (0.007, 0.062)
Cutuli, 2001^160^ | 145 | 91 | 0.021 (0.007, 0.062)
Cutuli, 2001^160^ | 435 | 91 | 0.083 (0.06, 0.113)
Silverstein, 2003^162^ | 280 | 81 | 0.175 (0.135, 0.224)
Schouten van der Velden, 2007^163^ | 408 | 59 | 0.027 (0.015, 0.048)
Schouten van der Velden, 2007^163^ | 153 | 59 | 0.072 (0.04, 0.125)
Schouten van der Velden, 2007^163^ | 237 | 59 | 0.257 (0.206, 0.317)
Schouten van der Velden, 2007^163^ | 408 | 59 | 0.027 (0.015, 0.048)
Schouten van der Velden, 2007^163^ | 408 | 59 | 0.027 (0.015, 0.048)
Schouten van der Velden, 2007^163^ | 153 | 59 | 0.072 (0.04, 0.125)
Kestin, 2000^171^ | 132 | 84 | 0.098 (0.058, 0.162)
Vicini, 2008^175^ | 195 | 28.6 | 0.015 (0.005, 0.047)
Vargas, 2005^181^ | 43 | 84 | 0.047 (0.012, 0.168)
Vargas, 2005^181^ | 367 | 84 | 0.082 (0.058, 0.115)
Vargas, 2005^181^ | 313 | 84 | 0.08 (0.055, 0.116)
Vargas, 2005^181^ | 54 | 84 | 0.093 (0.039, 0.204)
Cutuli, 2002^188^ | 515 | 84 | 0.128 (0.102, 0.16)
Silverstein, 2003^190^ | 259 | 88 | 0.189 (0.146, 0.242)
MacDonald, 2005^191^ | 445 | 57 | 0.178 (0.145, 0.216)
MacDonald, 2006^192^ | 272 | 53 | 0.048 (0.028, 0.081)
MacDonald, 2006^192^ | 212 | 53 | 0.057 (0.032, 0.097)
MacDonald, 2006^192^ | 60 | 53 | 0.017 (0.002, 0.109)
Nakamura, 2002^193^ | 260 | 105 | 0.185 (0.142, 0.236)
Silverstein, 1996^194^ | 138 | 79 | 0.167 (0.113, 0.238)
Silverstein, 1996^194^ | 195 | 79 | 0.164 (0.118, 0.223)
Silverstein, 1995^195^ | 187 | 78 | 0.011 (0.003, 0.042)
Silverstein, 1995^195^ | 238 | 78 | 0.13 (0.093, 0.179)
Silverstein, 1991^198^ | 109 | 51 | 0.009 (0.001, 0.062)
Silverstein, 1991^198^ | 104 | 51 | 0.067 (0.032, 0.135)
Amichett, 1997^199^ | 139 | 81 | 0.094 (0.055, 0.154)
Chuwa, 2008^200^ | 67 | 86 | 0.007 (0, 0.107)
Chuwa, 2008^200^ | 103 | 86 | 0.117 (0.067, 0.194)
Mirza, 2000^201^ | 109 | 132 in DCIS, 144 in DCIS with microinvasion | 0.147 (0.092, 0.226)
Chagpar, 2003^202^ | 109 | 11.4 | 0.009 (0.001, 0.062)
Adepoju, 2006^204^ | 211 | 103.2 | 0.066 (0.04, 0.109)
Adepoju, 2006^204^ | 92 | 103.2 | 0.185 (0.118, 0.277)
Adepoju, 2006^204^ | 310 | 103.2 | 0.139 (0.105, 0.182)
Takeda, 2001^205^ | 114 | 46.7 | 0.105 (0.061, 0.176)
Takeda, 2001^205^ | 48 | 46.7 | 0.042 (0.01, 0.152)
Takeda, 2001^205^ | 66 | 46.7 | 0.152 (0.084, 0.259)
Ben-David, 2007^206^ | 198 | 74.4 | 0.081 (0.05, 0.128)
Asjoe, 2007^207^ | 32 | 36 | 0.062 (0.016, 0.218)
Kestin, 2000^208^ | 177 | 84 | 0.085 (0.052, 0.136)
Kestin, 2000^208^ | 146 | 84 | 0.089 (0.052, 0.147)
Kestin, 2000^208^ | 31 | 84 | 0.065 (0.016, 0.224)
Lee, 2006^210^ | 1236 | 72 | 0.121 (0.104, 0.141)
Lee, 2006^210^ | 430 | 72 | 0.012 (0.005, 0.028)
Lee, 2006^210^ | 806 | 72 | 0.18 (0.155, 0.208)
Lee, 2006^210^ | 310 | 72 | 0.19 (0.15, 0.238)
Lee, 2006^210^ | 496 | 72 | 0.173 (0.143, 0.209)
Meijnen, 2008^211^ | 91 | 80.4 | 0.176 (0.111, 0.268)
Meijnen, 2008^211^ | 119 | 80.4 | 0.067 (0.034, 0.129)
Meijnen, 2008^211^ | 210 | 80.4 | 0.114 (0.078, 0.165)
Meijnen, 2008^211^ | 294 | 80.4 | 0.01 (0.003, 0.031)
Cataliotti, 1992^213^ | 183 | 94 | 0.06 (0.034, 0.105)
Cataliotti, 1992^213^ | 103 | 94 | 0.029 (0.009, 0.086)
Cataliotti, 1992^213^ | 34 | 94 | 0.088 (0.029, 0.24)
Cataliotti, 1992^213^ | 46 | 94 | 0.109 (0.046, 0.236)
Ciatto, 1990^214^ | 210 | 66 | 0.014 (0.005, 0.043)
Ciatto, 1990^214^ | 103 | 66 | 0.058 (0.026, 0.124)
Ciatto, 1990^214^ | 37 | 66 | 0.054 (0.014, 0.192)
Sahoo, 2005^216^ | 103 | 63 | 0.126 (0.075, 0.205)
Amichetti, 1999^217^ | 112 | 68 | 0.071 (0.036, 0.136)
Dimpfl, 1996^218^ | 161 | 78.4 | 0.056 (0.029, 0.104)
Dimpfl, 1996^218^ | 83 | 78.4 | 0.096 (0.049, 0.181)
Dimpfl, 1996^218^ | 78 | 78.4 | 0.013 (0.002, 0.085)
Dimpfl, 1996^218^ | 46 | 78.4 | 0.13 (0.06, 0.261)
Dimpfl, 1996^218^ | 37 | 78.4 | 0.054 (0.014, 0.192)
Vapiwala, 2006^219^ | 192 | 74.4 | 0.057 (0.032, 0.1)
Solin, 1996^221^ | 270 | 123.6 | 0.167 (0.127, 0.216)
Stallard, 2001^223^ | 67 | 132 | 0.007 (0, 0.107)
Szelei-Stevens, 2000^224^ | 43 | 104.4 | 0.14 (0.064, 0.278)
Van Zee, 1999^225^ | 157 | 74 | 0.21 (0.153, 0.281)
Bemitez, 2006^234^ | 100 | 9.5 | 0.02 (0.005, 0.076)
Douglas-Jones, 2002^235^ | 115 | NA | 0.122 (0.073, 0.195)
Gilleard, 2008^236^ | 215 | 53 | 0.088 (0.057, 0.134)
Omlin, 2006^237^ | 373 | 72 | 0.147 (0.115, 0.187)
Habel, 1998^238^ | 709 | 62 | 0.145 (0.121, 0.173)
Ottesen, 2000^240^ | 168 | 120 | 0.321 (0.255, 0.396)
Ottesen, 2000^240^ | 142 | 120 | 0.324 (0.252, 0.405)
Jha, 2001^242^ | 168 | 88 | 0.003 (0, 0.045)
Jha, 2001^242^ | 94 | 88 | 0.011 (0.001, 0.072)
Jha, 2001^242^ | 30 | 88 | 0.167 (0.071, 0.343)
Jha, 2001^242^ | 124 | 88 | 0.048 (0.022, 0.104)
Rakovitch, 2007^243^ | 310 | 82.8 | 0.21 (0.168, 0.259)
Rakovitch, 2007^243^ | 305 | 58.8 | 0.085 (0.059, 0.122)
Pinsky, 2007^244^ | 513 | NA | 0.082 (0.061, 0.109)
Carlson, 2007^245^ | 223 | 82.3 | 0.031 (0.015, 0.064)
Temple, 1989^247^ | 17 | 72 | 0.118 (0.03, 0.368)
Schouten van der Velden, 2006^250^ | 502 | 50.6 | 0.159 (0.13, 0.194)
Schouten van der Velden, 2006^250^ | 329 | 50.6 | 0.204 (0.164, 0.251)
Schouten van der Velden, 2006^250^ | 173 | 50.6 | 0.075 (0.044, 0.125)
Jhingran, 2002^251^ | 150 | 63 | 0.08 (0.046, 0.136)
Roka, 2004^254^ | 132 | 61.6 | 0.068 (0.036, 0.126)
Liberman, 1997^184^ | 162 | 75 | 0.204 (0.149, 0.273)
Liberman, 1997^184^ | 65 | 75 | 0.169 (0.096, 0.28)
Liberman, 1997^184^ | 97 | 75 | 0.227 (0.154, 0.321)
Ringberg, 2000^186^ | 119 | 63 | 0.034 (0.013, 0.086)
Ringberg, 2000^186^ | 66 | 63 | 0.076 (0.032, 0.169)
Ringberg, 2000^186^ | 121 | 63 | 0.256 (0.186, 0.341)
MacAusland, 2007^215^ | 222 | 55.2 | 0.086 (0.055, 0.13)
Warnek, 1995^182^ | 75 | 47 | 0.013 (0.002, 0.089)
Warnek, 1995^182^ | 21 | 37 | 0.023 (0.001, 0.277)
Warnek, 1995^182^ | 28 | 39 | 0.107 (0.035, 0.284)
Tunon-de-Lara, 2001^155^ | 208 | 86 | 0.014 (0.005, 0.044)
Jeruss, 2006^168^ | 158 | 7.35 | 0.003 (0, 0.048)
Warnberg, 1999^228^ | 46 | 58 | 0.022 (0.003, 0.139)
Holland, 1998^229^ | 129 | 35 | 0.093 (0.054, 0.157)
Holland, 1998^229^ | 68 | 35 | 0.103 (0.05, 0.201)
Holland, 1998^229^ | 41 | 35 | 0.122 (0.052, 0.261)
Holland, 1998^229^ | 20 | 35 | 0.024 (0.001, 0.287)
Fowble, 1997^230^ | 110 | 63.6 | 0.027 (0.009, 0.081)
Lara, 2003^231^ | 102 | 228 | 0.049 (0.021, 0.112)
Idvall, 2003^232^ | 121 | NA | 0.256 (0.186, 0.341)
Rodrigues, 2004^233^ | 101 | 34 | 0.02 (0.005, 0.076)
Bonnier, 1999^154^ | 214 | 51 | 0.019 (0.007, 0.049)
Bonnier, 1999^154^ | 319 | 51 | 0.091 (0.064, 0.128)
Bonnier, 1999^154^ | 42 | 51 | 0.119 (0.05, 0.256)
Tan, 2002^253^ | 101 | 32 | 0.03 (0.01, 0.088)
Warnberg, 2008^256^ | 213 | 155 | 0.268 (0.212, 0.331)
Rudloff, 2009^257^ | 294 | 132 | 0.214 (0.171, 0.265)
Rudloff, 2009^257^ | 294 | 180 | 0.29
Trisal, 2004^258^ | 171 | 70 | 0.111 (0.072, 0.168)
West, 2007, 17826074 | 71 | 99 | 0.014 (0.002, 0.093)
West, 2007, 17826074 | 153 | 98.4 | 0.039 (0.018, 0.085)
West, 2007, 17826074 | 82 | 86 | 0.061 (0.026, 0.138)
de Roos, 2005^261^ | 251 | 43 | 0.076 (0.049, 0.116)
de Roos, 2005^261^ | 130 | 43 | 0.023 (0.007, 0.069)
de Roos, 2005^261^ | 58 | 43 | 0.052 (0.017, 0.148)
de Roos, 2005^261^ | 63 | 43 | 0.206 (0.124, 0.324)
Cox, 1997^262^ | 103 | 60 | 0.08
Metz, 1999^266^ | 3 | 88.8 | 0.125 (0.007, 0.734)
Kepple, 2006^268^ | 94 | 48 | 0.043 (0.016, 0.108)
de Roos, 2007^270^ | 87 | 49.8 | 0.08 (0.039, 0.159)
Jiveliouk, 2009^271^ | 96 | 52 | 0.005 (0, 0.077)
Bellamy, 1993^281^ | 130 | 60 | 0.108 (0.065, 0.174)
Turaka, 2009^276^ | 440 | 180 | 0.08 (0.05, 0.14)
Ward, 1992^278^ | 178 | 120 | 0.017 (0.005, 0.051)
Silverstein, 2008^280^ | 896 | 87 | 0.18 (0.156, 0.206)
Tunon-de-Lara, 2001^155^ | 208 | 86 | 0.029 (0.013, 0.063)

Table F32 Total Local DCIS

Author | Number of Participants | Followup Duration | Rate (or Probability) of Events
Local DCIS Recurrence
Schouten van der Velden, 2006^250^ | 502 | 48 | 0.076
Jhingran, 2002^251^ | 150 | 60 | 0.01
Meijnen, 2008^211^ | 91 | 96 | 0.079
Meijnen, 2008^211^ | 119 | 96 | 0.014
Meijnen, 2008^211^ | 210 | 96 | 0.045
Meijnen, 2008^211^ | 294 | 96 | 0.005
Vicini, 2001^180^ | 148 | 86.4 | 0.027 (0.01, 0.07)
Lara, 2003^231^ | 102 | 228 | 0.039 (0.015, 0.1)
Chan, 2001^159^ | 129 | 47 | 0.14 (0.09, 0.211)
Chan, 2001^159^ | 18 | 47 | 0.111 (0.028, 0.352)
Chan, 2001^159^ | 49 | 47 | 0.102 (0.043, 0.223)
Chan, 2001^159^ | 9 | 47 | 0.111 (0.015, 0.5)
Chan, 2001^159^ | 18 | 47 | 0.111 (0.028, 0.352)
Chan, 2001^159^ | 49 | 47 | 0.102 (0.043, 0.223)
Chan, 2001^159^ | 9 | 47 | 0.111 (0.015, 0.5)
Chan, 2001^159^ | 18 | 47 | 0.111 (0.028, 0.352)
Chan, 2001^159^ | 49 | 47 | 0.102 (0.043, 0.223)
Chan, 2001^159^ | 9 | 47 | 0.111 (0.015, 0.5)
Chan, 2001^159^ | 18 | 47 | 0.111 (0.028, 0.352)
Chan, 2001^159^ | 9 | 47 | 0.111 (0.015, 0.5)
Chan, 2001^159^ | 9 | 47 | 0.111 (0.015, 0.5)
Cutuli, 2001^160^ | 716 | 91 | 0.057 (0.042, 0.077)
Cutuli, 2001^160^ | 145 | 91 | 0.003 (0, 0.052)
Cutuli, 2001^160^ | 145 | 91 | 0.003 (0, 0.052)
Cutuli, 2001^160^ | 435 | 91 | 0.138 (0.109, 0.174)
Silverstein, 2003^162^ | 280 | 81 | 0.086 (0.058, 0.125)
Kestin, 2000^171^ | 132 | 84 | 0.023 (0.007, 0.068)
Vargas, 2005^181^ | 367 | 84 | 0.033 (0.019, 0.057)
Fish, 1998^183^ | 18 | 60 | 0.026 (0.002, 0.31)
Fish, 1998^183^ | 106 | 60 | 0.179 (0.117, 0.264)
Fish, 1998^183^ | 88 | 60 | 0.193 (0.124, 0.289)
Fish, 1998^183^ | 18 | 60 | 0.111 (0.028, 0.352)
Cutuli, 2002^188^ | 515 | 84 | 0.05 (0.035, 0.073)
Silverstein, 2003^190^ | 259 | 88 | 0.1 (0.069, 0.143)
MacDonald, 2006^192^ | 272 | 53 | 0.033 (0.017, 0.062)
MacDonald, 2006^192^ | 212 | 53 | 0.042 (0.022, 0.08)
MacDonald, 2006^192^ | 60 | 53 | 0.008 (0.001, 0.118)
Nakamura, 2002^193^ | 260 | 105 | 0.1 (0.069, 0.143)
Silverstein, 1996^194^ | 138 | 79 | 0.08 (0.045, 0.138)
Silverstein, 1996^194^ | 195 | 79 | 0.092 (0.059, 0.142)
Silverstein, 1995^195^ | 238 | 78 | 0.071 (0.045, 0.112)
Silverstein, 1991^198^ | 104 | 51 | 0.048 (0.02, 0.11)
Amichett, 1997^199^ | 139 | 81 | 0.05 (0.024, 0.102)
Chuwa, 2008^200^ | 103 | 86 | 0.068 (0.033, 0.136)
Miller, 2001^203^ | 124 | 60 for L and 80.4 for M | 0.153 (0.1, 0.228)
Miller, 2001^203^ | 88 | 60 for L and 80.4 for M | 0.193 (0.124, 0.289)
Miller, 2001^203^ | 18 | 60 for L and 80.4 for M | 0.026 (0.002, 0.31)
Miller, 2001^203^ | 18 | 60 for L and 80.4 for M | 0.111 (0.028, 0.352)
Takeda, 2001^205^ | 114 | 46.7 | 0.044 (0.018, 0.101)
Ben-David, 2007^206^ | 198 | 74.4 | 0.061 (0.035, 0.104)
Kestin, 2000^208^ | 31 | 84 | 0.032 (0.005, 0.196)
Kestin, 2000^208^ | 146 | 84 | 0.021 (0.007, 0.062)
Kestin, 2000^208^ | 177 | 84 | 0.023 (0.009, 0.059)
Lee, 2006^210^ | 1236 | 72 | 0.07 (0.057, 0.086)
Lee, 2006^210^ | 430 | 72 | 0.005 (0.001, 0.018)
Lee, 2006^210^ | 806 | 72 | 0.105 (0.086, 0.129)
Lee, 2006^210^ | 310 | 72 | 0.09 (0.063, 0.128)
Lee, 2006^210^ | 496 | 72 | 0.115 (0.09, 0.146)
Meijnen, 2008^211^ | 91 | 80.4 | 0.077 (0.037, 0.153)
Meijnen, 2008^211^ | 119 | 80.4 | 0.008 (0.001, 0.057)
Meijnen, 2008^211^ | 210 | 80.4 | 0.038 (0.019, 0.074)
Meijnen, 2008^211^ | 294 | 80.4 | 0.003 (0, 0.024)
Cataliotti, 1992^213^ | 183 | 94 | 0.003 (0, 0.042)
Ciatto, 1990^214^ | 210 | 66 | 0.005 (0.001, 0.033)
Ciatto, 1990^214^ | 103 | 66 | 0.01 (0.001, 0.066)
Ciatto, 1990^214^ | 37 | 66 | 0.013 (0.001, 0.178)
Sahoo, 2005^216^ | 103 | 63 | 0.087 (0.046, 0.159)
Amichetti, 1999^217^ | 112 | 68 | 0.036 (0.013, 0.091)
Dimpfl, 1996^218^ | 161 | 78.4 | 0.05 (0.025, 0.096)
Solin, 1996^221^ | 270 | 123.6 | 0.078 (0.051, 0.116)
Szelei-Stevens, 2000^224^ | 43 | 104.4 | 0.047 (0.012, 0.168)
Warnberg, 1999^228^ | 46 | 58 | 0.022 (0.003, 0.139)
Holland, 1998^229^ | 129 | 35 | 0.078 (0.042, 0.138)
Fowble, 1997^230^ | 110 | 63.6 | 0.005 (0, 0.068)
Rodrigues, 2004^233^ | 101 | 34 | 0.01 (0.001, 0.067)
Bemitez, 2006^234^ | 100 | 9.5 | 0.02 (0.005, 0.076)
Douglas-Jones, 2002^235^ | 115 | NA | 0.052 (0.024, 0.111)
Gillear, 2008^236^ | 215 | 53 | 0.037 (0.019, 0.073)
Omlin, 2006^237^ | 373 | 72 | 0.075 (0.052, 0.107)
Habel, 1998^238^ | 709 | 62 | 0.068 (0.051, 0.089)
OttesenL, 2000^240^ | 168 | 120 | 0.173 (0.123, 0.237)
OttesenL, 2000^240^ | 142 | 120 | 0.183 (0.128, 0.255)
Jha, 2001^242^ | 124 | 88 | 0.024 (0.008, 0.072)
Rakovitch, 2007^243^ | 310 | 82.8 | 0.1 (0.071, 0.139)
Rakovitch, 2007^243^ | 305 | 58.8 | 0.062 (0.04, 0.096)
Carlson, 2007^245^ | 223 | 82.3 | 0.004 (0.001, 0.031)
Schouten van der Velden, 2006^250^ | 502 | 50.6 | 0.088 (0.066, 0.116)
Jhingran, 2002^251^ | 150 | 63 | 0.033 (0.014, 0.078)
Roka, 2004^254^ | 132 | 61.6 | 0.008 (0.001, 0.052)
Tan, 2002^253^ | 101 | 32 | 0.01 (0.001, 0.067)
Warnberg, 2008^256^ | 213 | 155 | 0.16 (0.116, 0.215)
Trisal, 2004^258^ | 171 | 70 | 0.076 (0.045, 0.127)
Innos, 2008^259^ | 14664 | 55 | 0.009 (0.008, 0.011)
Cox, 1997^262^ | 97 | 57.5 | 0.031 (0.01, 0.092)
Kepple, 2006^268^ | 94 | 48 | 0.032 (0.01, 0.094)
Bellamy, 1993^281^ | 130 | 60 | 0.046 (0.021, 0.099)
Turaka, 2009^276^ | 440 | 81.6 | 0.034 (0.021, 0.056)
Kinne, 1989^277^ | 101 | 138 | 0.005 (0, 0.073)
Rosner, 1980^279^ | 202 | 60 | 0.104
Silverstein, 2008, 19072459 | 896 | 87 | 0.1 (0.082, 0.122)
Temple, 1989^247^ | 17 | 72 | 0.059 (0.008, 0.32)

Figure F33 Total local invasive

Table F34 Observational studies of the association between control and systematic outcomes and tumor characteristics

Author, Study Design, and Adjusters | Treatments | Predictor | Followup Duration and Total Sample Size | Relative Risk or Hazard Ratio (95% CI)
Mammographic density/local DCIS or invasive carcinoma recurrence
Habel, 2004^179^ Study design: RCT^*^ Model: RR of local DCIS or invasive carcinoma recurrence, adjusted by age, BMI, and radiotherapy | L or LR | 25–49 vs. <25 | 132 months Total sample size: 392 | 1.3 (0.8; 2.4)
Habel, 2004^179^ Study design: RCT^*^ Model: RR of local DCIS or invasive carcinoma recurrence, adjusted by age, BMI, and radiotherapy | L or LR | 50–74 vs. <25 | 132 months Total sample size: 392 | 1.3 (0.6; 2.5)
Habel, 2004^179^ Study design: RCT^*^ Model: RR of local DCIS or invasive carcinoma recurrence, adjusted by age, BMI, and radiotherapy | L or LR | ≥75 vs. <25 | 132 months Total sample size: 392 | 3 (1.2; 7.5)
Mammographic density/local invasive carcinoma recurrence
Hwang, 2007^185^ Study design: OBS Model: HR of ipsilateral invasive cancer, adjusted by age and radiation | L or LR | High vs. low | 39 months Total sample size: 3,274 | 1 (0.6; 1.6)
Hwang, 2007^185^ Study design: OBS Model: HR of ipsilateral invasive cancer, adjusted by age in no radiation group | L or LR | High vs. low | 39 months Total sample size: 3,274 | 0.9 (0.5; 1.7)
Hwang, 2007^185^ Study design: OBS Model: HR of ipsilateral invasive cancer, adjusted by age in radiation group | L or LR | High vs. low | 39 months Total sample size: 3,274 | 1.1 (0.5; 2.5)
Mammographic density/contralateral DCIS or invasive carcinoma
Habel, 2004^179^ Study design: RCT^*^ Model: RR of contralateral DCIS or invasive carcinoma recurrence, adjusted by age, BMI, and radiotherapy | L or LR | High vs. low | 132 months Total sample size: 392 | 3.4 (0.7; 16.2)
Mammographic density/contralateral DCIS
Hwang, 2007^185^ Study design: OBS Model: HR of contralateral DCIS, adjusted by age and radiation | L or LR | High vs. low | 39 months Total sample size: 3,274 | 1.5 (0.6; 3.3)
Hwang, 2007^185^ Study design: OBS Model: HR of contralateral DCIS, adjusted by age in no radiation group | L or LR | High vs. low | 39 months Total sample size: 3,274 | 1.6 (0.5; 4.7)
Hwang, 2007^185^ Study design: OBS Model: HR of contralateral DCIS, adjusted by age in radiation group | L or LR | High vs. low | 39 months Total sample size: 3,274 | 0.8 (0.1; 4.4)
Mammographic density/contralateral invasive carcinoma
Hwang, 2007^185^ Study design: OBS Model: HR of contralateral invasive cancer, adjusted by age and radiation | L or LR | High vs. low | 39 months Total sample size: 3,274 | 3.1 (1.6; 6.1)
Hwang, 2007^185^ Study design: OBS Model: HR of contralateral invasive cancer, adjusted by age in no radiation group | L or LR | High vs. low | 39 months Total sample size: 3,274 | 2.7 (1; 7.5)
Hwang, 2007^185^ Study design: OBS Model: HR of contralateral invasive cancer, adjusted by age in radiation group | L or LR | High vs. low | 39 months Total sample size: 3,274 | 3.6 (1.1; 11.3)
Mammographic density/total DCIS or invasive carcinoma
Habel, 2004^179^ Study design: RCT^*^ Model: RR of total DCIS or invasive carcinoma, adjusted by age, BMI, and radiotherapy | L or LR | 25–49 vs. <25 | 132 months Total sample size: 392 | 1.1 (0.7; 1.8)
Habel, 2004^179^ Study design: RCT^*^ Model: RR of total DCIS or invasive carcinoma, adjusted by age, BMI, and radiotherapy | L or LR | 50–74 vs. <25 | 132 months Total sample size: 392 | 1.2 (0.7; 2.1)
Habel, 2004^179^ Study design: RCT^*^ Model: RR of total DCIS or invasive carcinoma, adjusted by age, BMI, and radiotherapy | L or LR | ≥75 vs. <25 | 132 months Total sample size: 392 | 2.8 (1.3; 6.1)
Mammographic density/total invasive carcinoma
Habel, 2004^179^ Study design: RCT^*^ Model: RR of total invasive carcinoma, adjusted by age, BMI, and radiotherapy | L or LR | 25–49 vs. <25 | 132 months Total sample size: 392 | 1 (0.7; 2.8)
Habel, 2004^179^ Study design: RCT^*^ Model: RR of total invasive carcinoma, adjusted by age, BMI, and radiotherapy | L or LR | 50–74 vs. <25 | 132 months Total sample size: 392 | 1.4 (0.7; 2.8)
Habel, 2004^179^ Study design: RCT^*^ Model: RR of total invasive carcinoma, adjusted by age, BMI, and radiotherapy | L or LR | ≥75 vs. <25 | 132 months Total sample size: 392 | 3.2 (1.2; 8.5)
Hwang, 2007^185^ Study design: OBS Model: HR of any invasive cancer, adjusted by age and radiation | L or LR | High vs. low | 39 months Total sample size: 3,274 | 1.4 (0.9; 2.1)
Hwang, 2007^185^ Study design: OBS Model: HR of any invasive cancer, adjusted by age in no radiation group | L or LR | High vs. low | 39 months Total sample size: 3,274 | 1.2 (0.7; 2)
Hwang, 2007^185^ Study design: OBS Model: HR of any invasive cancer, adjusted by age in radiation group | L or LR | High vs. low | 39 months Total sample size: 3,274 | 1.7 (0.8; 3.3)
Margin/local DCIS or invasive carcinoma recurrence
Bijker, 2006^282^ Study design: RCT Model: HR of local DCIS or invasive carcinoma recurrence adjusted by age, method of detection, histology, pathology, margin, and treatment | LR vs. L | Not free vs. free, adjusted by age, method of detection, histology, pathology, margin, and treatment | 126 months Total sample size: 1,010 | 1.84 (1.32; 2.56)
Fisher, 1999^283^ Study design: RCT Model: RR of local DCIS or invasive carcinoma recurrence, adjusted for treatment | LR vs. L | Uncertain/involved vs. free | 102 months Total sample size: 818 | 1.48 (0.98; 2.21)
Fisher, 2001^284^ Study design: RCT Model: RR of local DCIS or invasive carcinoma recurrence in given covariate stratum, adjusted for treatment | LRT vs. LR | Not free or unknown vs. free | 83 months Total sample size: 1,804 | 1.84 (1.35; 2.51)
Omlin, 2006^237^ Study design: OBS Model: HR of 10-year local DCIS or invasive recurrence, adjusted by age, method of detection, tumor size, necrosis, grade, margin, ER status, and treatment | LR or L | Positive vs. free | 72 months Total sample size: 373 | 3.53 (1.48; 8.43)
Vicini, 2001^180^ Study design: OBS Model: HR of ipsilateral failure, adjusted by age, calcifications, number of slides with DCIS, margin, numbers of DCIS/COL foci ≤5mm from margin, tumor size, nuclear grade, comedonecrosis, and total volume of excision | LR | Close/involved vs. free | 86.4 months Total sample size: 148 | 2.49^*^
Vicini, 2001^180^ Study design: OBS Model: HR of ipsilateral failure, adjusted by age, calcifications, number of slides with DCIS/total volume, margin, numbers of DCIS/COL foci ≤5mm from margin, tumor size, nuclear grade, and comedonecrosis | LR | Close/involved vs. free | 86.4 months Total sample size: 148 | 2.59^*^
Vargas, 2005^181^ Study design: OBS Model: HR of ipsilateral failure, adjusted by age, preradiation mammogram, mass in mammogram, boost energy, and margin | LR or L | Positive, ≤2mm, 3–5mm, >5mm | 84 months Total sample size: 410 | 1.82 *
Vicini, 2000^174^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by age, calcification, number of slides with DCIS, margin, number of DCIS or COL foci ≤5mm from margin, tumor size, nuclear grade, necrosis, method of detection, and excision volume | LR | Close/involved vs. free | 86.4 months Total sample size: 148 | 2.49^*^
Vicini, 2000^174^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by age, calcification, number of slide with DCIS, margin, number of DCIS or COL foci ≤5mm from margin, tumor size, nuclear grade, necrosis, method of detection, and re-excision volume | LR | Close/involved vs. free | 86.4 months Total sample size: 148 | 3.78 *
Schouten van der Velden, 2007^163^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by age, method of detection, necrosis, treatment, size, and margin | M, MR, L, LR | Close/involved vs. free | 59 months Total sample size: 798 | 1.8 (0.96; 3.4)
Schouten van der Velden, 2007^163^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by age, method of detection, necrosis, treatment, size, and margin | LR or L | Close/involved vs. free | 59 months Total sample size: 798 | 2 (1.1; 4)
Meijnen, 2008^211^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by age, method of detection, treatment, margins, and grades | M, LR or L | Not free vs. free | 80.4 months Total sample size: 504 | 5.75 (2.44; 13.56)
Sahoo, 2005^216^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by margin, age, grade, necrosis, and size | LR | Positive vs. negative | 63 months Total sample size: 103 | 6.25 (1.59; 25)
Ben-David, 2007^206^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted in multivariate analysis, unspecified | LR or LRT | Close vs. free | 74.4 months Total sample size: 198 | 4.11 (1.11; 15.18)
Ben-David, 2007^206^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted in multivariate analysis, unspecified | LR or LRT | Positive vs. free | 74.4 months Total sample size: 198 | 9.01 (1.84; 44.13)
Warren, 2005^164^ Study design: OBS Model: HR of local DCIS or invasive carcinoma, adjusted for demographic and clinical factors | L, LR, LT, or LRT | Involved vs. free | 91 months Total sample size: 1,103 | 1.19 (0.69; 2.06)
Rakovitch, 2007^243^ Study design: OBS Model: HR of local DCIS or invasive recurrence, adjusted by radiation, nuclear grade, multifocality, and margin | LR or L | <4mm vs. >4mm | NA months Total sample size: 310 | 1.74 (1.03; 2.92)
Cutuli, 2001^160^ Study design: OBS Model: HR of local recurrence (not specific) adjusted by treatment, age, method of detection, margin, and family history | LR | Involved vs. free | 91 months Total sample size: 716 | 1.83 (1.1; 3.05)
Solin, 2005^152^ Study design: OBS Model: HR of local recurrence (not specified) adjusted by age, margin, mammographic findings, institution, date, location of primary tumor, and irradiation dose | LR | Positive margin vs. margin free ≥2–3mm | 102 months Total sample size: 1,003 | 3.35 *
Solin, 2005^152^ Study design: OBS Model: HR of local recurrence (not specified) adjusted by age, margin, mammographic findings, institution, date, location of primary tumor, and irradiation dose | LR | 0–2 or 3mm vs. margin free ≥2–3mm | 102 months Total sample size: 1,003 | 1.9 *
Vicini, 2000^174^ Study design: OBS Model: HR of true DCIS or invasive carcinoma recurrence, adjusted by age, calcification, number of slides with DCIS, margin, number of DCIS or COL foci ≤5mm from margin, tumor size, nuclear grade, necrosis, method of detection, and excision volume | LR | Close/involved vs. free | 86.4 months Total sample size: 148 | 4.47 *
Vicini, 2000^174^ Study design: OBS Model: HR of true DCIS or invasive carcinoma recurrence, adjusted by age, calcification, number of slides with DCIS, margin, number of DCIS or COL foci ≤5mm from margin, tumor size, nuclear grade, necrosis, method of detection, and re-excision volume | LR | Close/involved vs. free | 86.4 months Total sample size: 148 | 7.78 *
Vicini, 2001^180^ Study design: OBS Model: HR of true DCIS or invasive carcinoma recurrence, adjusted by age, calcifications, number of slides with DCIS, margin, numbers of DCIS/COL foci ≤5mm from margin, tumor size, nuclear grade, comedonecrosis, and total volume of excision | LR | Close/involved vs. free | 86.4 months Total sample size: 148 | 4.47 *
Chuwa, 2008^200^ Study design: OBS Model: local DCIS or invasive carcinoma recurrence, adjusted by age, menopausal status, symptom, grade, size, hormone receptor status, necrosis, margin, radiation, tamoxifen | M, MT, LR, LRT, LT or L | Involved vs. free | 86 months Total sample size: 170 | 3.7 (1.03; 14.29)
Boland, 2003^173^ Study design: OBS Model: RR of local DCIS or invasive carcinoma recurrence, adjusted by margin, grade, tumor size | L, LR, LT, or LRT | <1mm vs. ≥1mm | 47 months Total sample size: 237 | 9.8 (4.5; 21)
MacDonald, 2005^191^ Study design: OBS Model: RR of local DCIS or invasive carcinoma recurrence, adjusted by margin, age, grade, tumor size, and necrosis | L | <10mm vs. >10mm | 57 months Total sample size: 445 | 5.39 (2.68; 10.64)
MacDonald, 2005^191^ Study design: OBS Model: RR of local DCIS or invasive carcinoma recurrence, adjusted by margin, age, grade, tumor size, and necrosis | L | Involved vs. >10mm | 57 months Total sample size: 445 | 7.69^*^
Cutuli, 2002^188^ Study design: OBS Model: RR of local DCIS or invasive carcinoma recurrence, adjusted by age, tumor stage, margin, and family history | L | Positive/unknown vs. free | 84 months Total sample size: 705 | 1.64 (1.08; 2.49)
Cutuli, 2002^188^ Study design: OBS Model: RR of local DCIS or invasive carcinoma recurrence, adjusted by age, tumor stage, margin, and family history | LR | Positive/unknown vs. free | 84 months Total sample size: 705 | 1.39 (1.06; 1.82)
Kerlikowske, 2003^166^ Study design: OBS Model: OR of ipsilateral DCIS or invasive carcinoma recurrence, adjusted by age, tumor size, margin, nuclear grade, quantity of necrosis, and cell polarity | L | Positive vs. >10mm | 77.9 months Total sample size: 1,036 | 3.5 (1.6; 7.5)
Kerlikowske, 2003^166^ Study design: OBS Model: OR of ipsilateral DCIS or invasive carcinoma recurrence, adjusted by age, tumor size, margin, nuclear grade, quantity of necrosis, and cell polarity | L | Uncertain vs. >10mm | 77.9 months Total sample size: 1,036 | 3.0 (1.4; 6.7)
Kerlikowske, 2003^166^ Study design: OBS Model: OR of ipsilateral DCIS or invasive carcinoma recurrence, adjusted by age, tumor size, margin, nuclear grade, quantity of necrosis, and cell polarity | L | 1–1.9mm vs. >10mm | 77.9 months Total sample size: 1,036 | 2.5 (1.1; 5.9)
Kerlikowske, 2003^166^ Study design: OBS Model: OR of ipsilateral DCIS or invasive carcinoma recurrence, adjusted by age, tumor size, margin, nuclear grade, quantity of necrosis, and cell polarity | L | 2–10mm vs. >10mm | 77.9 months Total sample size: 1,036 | 3.1 (1.1; 9.0)
Margin/local DCIS recurrence
Warren, 2005^164^ Study design: OBS Model: OR of local DCIS, adjusted for demographic and clinical factors | L, LR, LT, or LRT | Involved vs. free | 91 months Total sample size: 1,103 | 0.86 (0.4; 1.86)
Kerlikowske, 2003^166^ Study design: OBS Model: OR of ipsilateral DCIS recurrence, adjusted by age, tumor size, margin, nuclear grade, and cell polarity | L | Positive vs. >10mm | 77.9 months Total sample size: 1,036 | 6.9 (1.9; 25.2)
Kerlikowske, 2003^166^ Study design: OBS Model: OR of ipsilateral DCIS recurrence, adjusted by age, tumor size, margin, nuclear grade, and cell polarity | L | Uncertain vs. >10mm | 77.9 months Total sample size: 1,036 | 11.4 (2.4; 53.9)
Kerlikowske, 2003^166^ Study design: OBS Model: OR of ipsilateral DCIS recurrence, adjusted by age, tumor size, margin, nuclear grade, and cell polarity | L | 1–1.9mm vs. >10mm | 77.9 months Total sample size: 1,036 | 6.5 (1.6; 26.1)
Kerlikowske, 2003^166^ Study design: OBS Model: OR of ipsilateral DCIS recurrence, adjusted by age, tumor size, margin, nuclear grade, and cell polarity | L | 2–10mm vs. >10mm | 77.9 months Total sample size: 1,036 | 6.6 (1.1; 38.1)
Margin/local invasive carcinoma recurrence
Warren, 2005^164^ Study design: OBS Model: OR of local invasive carcinoma, adjusted for demographic and clinical factors | L, LR, LT, or LRT | Involved vs. free | 91 months Total sample size: 1,103 | 1.39 (0.58; 3.31)
Vicini, 2000^174^ Study design: OBS Model: HR of true invasive carcinoma recurrence, adjusted by age, calcification, number of slides with DCIS, margin, number of DCIS or COL foci ≤5mm from margin, tumor size, nuclear grade, necrosis, method of detection, and re-excision volume | LR | Close/involved vs. free | 86.4 months Total sample size: 148 | 3.26^*^
Kerlikowske, 2003^166^ Study design: OBS Model: OR of ipsilateral invasive carcinoma recurrence, adjusted by detection method, margin, nuclear grade, and type of calcification | L | Positive vs. >10mm | 77.9 months Total sample size: 1,036 | 2.7 (0.7; 9.4)
Kerlikowske, 2003^166^ Study design: OBS Model: OR of ipsilateral invasive carcinoma recurrence, adjusted by detection method, margin, nuclear grade, and type of calcification | L | Uncertain vs. >10mm | 77.9 months Total sample size: 1,036 | 1.2 (0.4; 3.5)
Kerlikowske, 2003^166^ Study design: OBS Model: OR of ipsilateral invasive carcinoma recurrence, adjusted by detection method, margin, nuclear grade, and type of calcification | L | 1–1.9mm vs. >10mm | 77.9 months Total sample size: 1,036 | 0.9 (0.3; 3.0)
Kerlikowske, 2003^166^ Study design: OBS Model: OR of ipsilateral invasive carcinoma recurrence, adjusted by detection method, margin, nuclear grade, and type of calcification | L | 2–10mm vs. >10mm | 77.9 months Total sample size: 1,036 | 1.1 (0.2; 6.3)
Margin (log transformed)/local invasive carcinoma recurrence
MacDonald, 2005^191^ Study design: OBS Model: RR of local DCIS or invasive carcinoma recurrence, adjusted by margin, age, grade, tumor size, and necrosis | L | Log transformed margin | 57 months Total sample size: 445 | 0.42 (0.32; 0.56)
Tumor size/local DCIS or invasive carcinoma recurrence
Fisher, 1999^283^ Study design: RCT Model: RR of local DCIS or invasive carcinoma recurrence, adjusted for treatment | LR vs. L | ≥10 vs. <10 | 102 months Total sample size: 818 | 1.2 (0.74; 1.96)
Fisher, 1999^283^ Study design: RCT Model: RR of local DCIS or invasive carcinoma recurrence, adjusted for treatment | LR vs. L | ≥5–10 vs. <5 | 102 months Total sample size: 818 | 1.37 (0.74; 2.55)
Omlin, 2006^237^ Study design: OBS Model: HR of 10-year local DCIS or invasive recurrence, adjusted by age, method of detection, tumor size, necrosis, grade, margin, ER status, and treatment | LR or L | >20mm vs. ≤20mm | 72 months Total sample size: 373 | 1.16 (0.5; 2.68)
Omlin, 2006^237^ Study design: OBS Model: HR of 10-year local DCIS or invasive recurrence, adjusted by age, method of detection, tumor size, necrosis, grade, margin, ER status, and treatment | LR or L | Unknown vs. ≤20mm | 72 months Total sample size: 373 | 1.95 (1.02; 3.72)
Ottesen, 2000^240^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by tumor size, necrosis, and nuclear size | L | ≥10mm vs. <10mm | 120 months Total sample size: 168 | 5.3 (2.1; 13.2)
Warren, 2005^164^ Study design: OBS Model: HR of local DCIS or invasive carcinoma, adjusted for demographic and clinical factors | L, LR, LT, or LRT | 1–<2cm vs. <1cm | 91 months Total sample size: 1,103 | 0.99 (0.67; 1.45)
Warren, 2005^164^ Study design: OBS Model: HR of local DCIS or invasive carcinoma, adjusted for demographic and clinical factors | L, LR, LT, or LRT | ≥2cm vs. <1cm | 91 months Total sample size: 1,103 | 1.54 (0.98; 2.44)
Cornfield, 2004^157^ Study design: OBS Model: odds of local DCIS or invasive recurrence, adjusted by tumor size and necrosis | L | >15 mm vs. ≤15mm | 65 months Total sample size: 151 | 4.1 (1.8; 9.5)
Boland, 2003^173^ Study design: OBS Model: RR of local DCIS or invasive carcinoma recurrence | L, LR, LT, or LRT | 16–40mm vs. ≤15mm | 47 months Total sample size: 237 | 1.2 (0.6; 2.4)
MacDonald, 2005^191^ Study design: OBS Model: RR of local DCIS or invasive carcinoma recurrence, adjusted by margin, age, grade, tumor size, and necrosis | L | Log transformed tumor size | 57 months Total sample size: 445 | 1.21 (1.1; 1.34)
MacDonald, 2005^191^ Study design: OBS Model: RR of local DCIS or invasive carcinoma recurrence, adjusted by margin, age, grade, tumor size, and necrosis | L | 40m vs. 1mm | 57 months Total sample size: 445 | 2.81^*^
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | ≥15mm vs. <15mm | 62 months Total sample size: 709 | 1.6 (0.9; 2.9)
Tumor size/local DCIS recurrence
Smith, 2006^151^ Study design: OBS Model: HR of local DCIS recurrence adjusted by age, race, comorbidity, tumor size, histology, grade, treatment, marital status, median income, urban-rural status | LR or L | Tumor size as continuous variable | 60 months Total sample size: 3,409 | 1.11 (0.85; 1.46)
Warren, 2005^164^ Study design: OBS Model: OR of local DCIS, adjusted for demographic and clinical factors | L, LR, LT, or LRT | 1–<2cm vs. <1cm | 91 months Total sample size: 1,103 | 1.01 (0.59; 1.73)
Warren, 2005^164^ Study design: OBS Model: OR of local DCIS, adjusted for demographic and clinical factors | L, LR, LT, or LRT | ≥2cm vs. <1cm | 91 months Total sample size: 1,103 | 1.66 (0.88; 3.11)
Kerlikowske, 2003^166^ Study design: OBS Model: OR of ipsilateral DCIS recurrence, adjusted by age, tumor size, margin, nuclear grade, and cell polarity | L | >10mm vs. ≤ 10mm | 77.9 months Total sample size: 1,036 | 1.9 (0.9; 4.1)
Tumor size/local invasive carcinoma recurrence
Smith, 2006^151^ Study design: OBS Model: HR of local invasive carcinoma recurrence adjusted by age, race, comorbidity, tumor size, histology, grade, treatment, marital status, median income, urban-rural status | LR or L | Tumor size as continuous variable | 60 months Total sample size: 3,409 | 1.16 (0.98; 1.38)
Li, 2006^249^ Study design: OBS Model: HR of local invasive carcinoma recurrence, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | 20–49mm vs. <20mm | NA months Total sample size: 37,692 | 0.9 (0.6; 1.2)
Li, 2006^249^ Study design: OBS Model: HR of local invasive carcinoma recurrence, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | ≥50mm vs. <20mm | NA months Total sample size: 37,692 | 1 (0.5; 2.3)
Warnberg, 2001^226^ Study design: OBS Model: OR of ipsilateral invasive recurrence, adjusted by age, size, and treatment | M, LR, or L | ≥25mm vs. <25mm | NA months Total sample size: NA | 2.3 (0.7; 7)
Warren, 2005^164^ Study design: OBS Model: OR of local invasive carcinoma, adjusted for demographic and clinical factors | L, LR, LT, or LRT | 1–<2cm vs. <1cm | 91 months Total sample size: 1,103 | 0.94 (0.52; 1.72)
Warren, 2005^164^ Study design: OBS Model: OR of local invasive carcinoma, adjusted for demographic and clinical factors | L, LR, LT, or LRT | ≥2cm vs. <1cm | 91 months Total sample size: 1,103 | 1.23 (0.58; 2.64)
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by followup time and age | LR or L | ≥15mm vs. <15mm | 62 months Total sample size: 709 | 1.6 (0.7; 3.5)
Tumor size/contralateral invasive carcinoma
Li, 2006^249^ Study design: OBS Model: HR of contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | 20–49mm vs. <20mm | NA months Total sample size: 37,692 | 0.9 (0.7; 1.1)
Li, 2006^249^ Study design: OBS Model: HR of contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | ≥50mm vs. <20mm | NA months Total sample size: 37,692 | 1.3 (0.8; 1.9)
Warnberg, 2001^226^ Study design: OBS Model: OR of contralateral invasive recurrence, adjusted by age, size, and treatment | M, LR, or L | ≥25mm vs. <25mm | NA months Total sample size: NA | 1.7 (0.5; 5.1)
Tumor size/any invasive carcinoma
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | 20–49mm vs. <20mm | NA months Total sample size: 37,692 | 0.9 (0.7; 1.1)
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | ≥50mm vs. <20mm | NA months Total sample size: 37,692 | 1.3 (0.9; 1.8)
Tumor size/any DCIS or invasive carcinoma
Smith, 2006^151^ Study design: OBS Model: HR of any second breast cancer event (local DCIS, local invasive carcinoma, and/or subsequent mastectomy) adjusted by age, race, comorbidity, tumor size, histology, grade, treatment, marital status, median income, urban-rural status | LR or L | Tumor size as continuous variable | 60 months Total sample size: 3,409 | 1.14 (1.02; 1.26)
Tumor size/breast cancer death
Warnberg, 2001^226^ Study design: OBS Model: OR of breast cancer death, adjusted by age, size, and treatment | M, LR, or L | ≥25mm vs. <25mm | NA months Total sample size: NA | 2.9 (0.8; 10.1)
Pathologic grade/local DCIS or invasive carcinoma recurrence
Bijker, 2006^282^ Study design: RCT Model: HR of local DCIS or invasive carcinoma recurrence adjusted by age, method of detection, histology, pathology, margin, and treatment | LR vs. L | Intermediate vs. well | 126 months Total sample size: 1,010 | 1.85 (1.18; 2.9)
Bijker, 2006^282^ Study design: RCT Model: HR of local DCIS or invasive carcinoma recurrence adjusted by age, method of detection, histology, pathology, margin, and treatment | LR vs. L | Poor vs. well | 126 months Total sample size: 1,010 | 1.61 (0.93; 2.79)
Meijnen, 2008^211^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by age, method of detection, treatment, margins, and grades | M, LR or L | Intermediate vs. well | 80.4 months Total sample size: 504 | 0.96 (0.35; 2.66)
Meijnen, 2008^211^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by age, method of detection, treatment, margins, and grades | M, LR or L | Poor vs. well | 80.4 months Total sample size: 504 | 1.3 (0.39; 4.27)
Pathologic grade/local DCIS recurrence
Smith, 2006^151^ Study design: OBS Model: HR of local DCIS recurrence adjusted by age, race, cormobidity, tumor size, histology, grade, treatment, martial status, median income, urban-rural status | LR or L | Medium vs. low | 60 months Total sample size: 3,409 | 1.47 (0.43; 4.98)
Smith, 2006^151^ Study design: OBS Model: HR of local DCIS recurrence adjusted by age, race, cormobidity, tumor size, histology, grade, treatment, martial status, median income, urban-rural status | LR or L | High vs. low | 60 months Total sample size: 3409 | 2.87 (0.81; 10.26)
Pathologic grade/local invasive carcinoma recurrence
Smith, 2006^151^ Study design: OBS Model: HR of local invasive carcinoma recurrence adjusted by age, race, comorbidity, tumor size, histology, grade, treatment, marital status, median income, urban-rural status | LR or L | Medium vs. low | 60 months Total sample size: 3409 | 2.12 (0.69; 6.52)
| LR or L | High vs. low | 60 months Total sample size: 3409 | 2.22 (0.65; 7.57)
Li, 2006^249^ Study design: OBS Model: HR of local invasive carcinoma recurrence, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Moderate vs. well | NA months Total sample size: 37,692 | 1.3 (0.8; 1.9)
Li, 2006^249^ Study design: OBS Model: HR of local invasive carcinoma recurrence, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Poor vs. well | NA months Total sample size: 37,692 | 2 (1.3; 3.1)
Pathologic grade/contralateral invasive carcinoma
Li, 2006^249^ Study design: OBS Model: HR of contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Moderate vs. well | NA months Total sample size: 37,692 | 1.1 (0.8; 1.6)
Li, 2006^249^ Study design: OBS Model: HR of contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Poor vs. well | NA months Total sample size: 37,692 | 0.8 (0.5; 1.1)
Pathologic grade/any invasive carcinoma
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Moderate vs. well | NA months Total sample size: 37,692 | 1.2 (0.9; 1.5)
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Poor vs. well | NA months Total sample size: 37,692 | 1.2 (0.9; 1.6)
Pathologic grade/any DCIS or invasive cancer
Smith, 2006^151^ Study design: OBS Model: HR of any second breast cancer event (local DCIS, local invasive carcinoma, and/or subsequent mastectomy) adjusted by age, race, comorbidity, tumor size, histology, grade, treatment, marital status, median income, urban-rural status | LR or L | Medium vs. low | 60 months Total sample size: 3,409 | 1.49 (0.81; 2.72)
| LR or L | High vs. low | 60 months Total sample size: 3,409 | 2.38 (1.24; 4.56)
Nuclear grade/local DCIS or invasive carcinoma recurrence
Fisher, 1999^283^ Study design: RCT Model: RR of local DCIS or invasive carcinoma recurrence, adjusted for treatment | LR vs. L | Poor vs. good | 102 months Total sample size: 818 | 1.36 (0.97; 1.9)
Omlin, 2006^237^ Study design: OBS Model: HR of 10-year local DCIS or invasive recurrence, adjusted by age, method of detection, tumor size, necrosis, grade, margin, ER status, and treatment | LR or L | 2 vs. 1 | 72 months Total sample size: 373 | 1.01 (0.36; 2.79)
Omlin, 2006^237^ Study design: OBS Model: HR of 10-year local DCIS or invasive recurrence, adjusted by age, method of detection, tumor size, necrosis, grade, margin, ER status, and treatment | LR or L | 3 vs. 1 | 72 months Total sample size: 373 | 1.46 (0.56; 3.8)
Omlin, 2006^237^ Study design: OBS Model: HR of 10-year local DCIS or invasive recurrence, adjusted by age, method of detection, tumor size, necrosis, grade, margin, ER status, and treatment | LR or L | Unknown vs. 1 | 72 months Total sample size: 373 | 1.23 (0.5; 3.01)
Sahoo, 2005^216^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by margin, age, grade, necrosis, and size | LR | Grade 3 vs. 1 or 2 | 63 months Total sample size: 103 | 4.17 (1.18; 14.73)
Rakovitch, 2007^243^ Study design: OBS Model: HR of local DCIS or invasive recurrence, adjusted by radiation, nuclear grade, multifocality, and margin | LR or L | High vs. not high | NA months Total sample size: 310 | 1.65 (1.02; 2.65)
Rakovitch, 2007^243^ Study design: OBS Model: HR of local DCIS or invasive recurrence, adjusted by radiation, nuclear grade, multifocality, and margin, in negative margin cases | LR or L | High vs. not high | NA months Total sample size: 310 | 1.82 (1.09; 3.03)
Rakovitch, 2007^243^ Study design: OBS Model: HR of local DCIS or invasive recurrence, adjusted by radiation, nuclear grade, multifocality, and margin, in negative margin cases | LR or L | Unreported vs. not high | NA months Total sample size: 310 | 2.14 (1.09; 4.2)
Vicini, 2000^174^ Study design: OBS Model: HR of true invasive carcinoma recurrence, adjusted by age, calcification, number of slides with DCIS, margin, number of DCIS or COL foci ≤5mm from margin, tumor size, nuclear grade, necrosis, method of detection, and re-excision volume | LR | 3 vs. 1–2 | 86.4 months Total sample size: 148 | 8.86 *
Ringberg, 2001^187^ Study design: OBS Model: RR of local DCIS or invasive carcinoma recurrence free interval, adjusted by CBI-7, grade, and growth pattern | L | High vs. low | 62 months Total sample size: 121 | 1.4 (0.5; 4.2)
Idvall, 2003^232^ Study design: OBS Model: RR of local DCIS or invasive carcinoma recurrence free interval, adjusted by mitotic frequency, grade, and growth pattern | L | 3 vs. 1 and 2 | NA months Total sample size: 121 | 1.9 (0.8; 4.7)
Idvall, 2003^232^ Study design: OBS Model: RR of local DCIS or invasive carcinoma recurrence free interval, adjusted by polarisation, grade, and growth pattern | L | 3 vs. 1 and 2 | NA months Total sample size: 121 | 2.1 (1; 4.7)
MacDonald, 2005^191^ Study design: OBS Model: RR of local DCIS or invasive carcinoma recurrence, adjusted by margin, age, grade, tumor size, and necrosis | L | 3 vs. 1 or 2 | 57 months Total sample size: 445 | 3.44 (1.74; 6.79)
Boland, 2003^173^ Study design: OBS Model: RR of local DCIS or invasive carcinoma recurrence, adjusted by margin, grade, tumor size | L, LR, LT, or LRT | 3 vs. 2 | 47 months Total sample size: 237 | 2.1 (0.9; 4.6)
Kerlikowske, 2003^166^ Study design: OBS Model: OR of ipsilateral DCIS or invasive carcinoma recurrence, adjusted by age, tumor size, margin, nuclear grade, quantity of necrosis, and cell polarity | L | High vs. low | 77.9 months Total sample size: 1,036 | 4.6 (2.2; 9.5)
Kerlikowske, 2003^166^ Study design: OBS Model: OR of ipsilateral DCIS or invasive carcinoma recurrence, adjusted by age, tumor size, margin, nuclear grade, quantity of necrosis, and cell polarity | L | Intermediate vs. low | 77.9 months Total sample size: 1,036 | 2.1 (1.1; 4.2)
Warren, 2005^164^ Study design: OBS Model: HR of local DCIS or invasive carcinoma, adjusted for demographic and clinical factors | L, LR, LT, or LRT | High vs. low | 91 months Total sample size: 1,103 | 1.76 (1.23; 2.52)
Nuclear grade/local DCIS recurrence
Kerlikowske, 2003^166^ Study design: OBS Model: OR of ipsilateral DCIS recurrence, adjusted by age, tumor size, margin, nuclear grade, and cell polarity | L | High vs. low | 77.9 months Total sample size: 1,036 | 6.2 (2.0; 19.1)
Kerlikowske, 2003^166^ Study design: OBS Model: OR of ipsilateral DCIS recurrence, adjusted by age, tumor size, margin, nuclear grade, and cell polarity | L | Intermediate vs. low | 77.9 months Total sample size: 1,036 | 1.7 (0.6; 4.5)
Warren, 2005^164^ Study design: OBS Model: OR of local DCIS, adjusted for demographic and clinical factors | L, LR, LT, or LRT | High vs. low | 91 months Total sample size: 1,103 | 2.14 (1.31; 3.51)
Nuclear grade/local invasive carcinoma recurrence
Kerlikowske, 2003^166^ Study design: OBS Model: OR of ipsilateral invasive carcinoma recurrence, adjusted by detection method, margin, nuclear grade, and type of calcification | L | High vs. low | 77.9 months Total sample size: 1,036 | 4.5 (1.2; 16.3)
Kerlikowske, 2003^166^ Study design: OBS Model: OR of ipsilateral invasive carcinoma recurrence, adjusted by detection method, margin, nuclear grade, and type of calcification | L | Intermediate vs. low | 77.9 months Total sample size: 1,036 | 1.8 (0.6; 6.1)
Warren, 2005^164^ Study design: OBS Model: OR of local invasive carcinoma, adjusted for demographic and clinical factors | L, LR, LT, or LRT | High vs. low | 91 months Total sample size: 1,103 | 1.03 (0.58; 1.85)
Nuclear grade/any DCIS or invasive carcinoma recurrence
Stallard, 2001^223^ Study design: OBS Model: HR of any DCIS or invasive carcinoma recurrence, adjusted by distance from nipple to lesion, grade, and radiation | M, LR, LT, LRT, or L | Per unit change | 132 months Total sample size: 220 | 0.45 (0.21; 0.98)
ER status/local DCIS or invasive carcinoma recurrence
Omlin, 2006^237^ Study design: OBS Model: HR of 10-year local DCIS or invasive recurrence, adjusted by age, method of detection, tumor size, necrosis, grade, margin, ER status, and treatment | LR or L | Positive vs. negative | 72 months Total sample size: 373 | 0.71 (0.17; 2.96)
Omlin, 2006^237^ Study design: OBS Model: HR of 10-year local DCIS or invasive recurrence, adjusted by age, method of detection, tumor size, necrosis, grade, margin, ER status, and treatment | LR or L | Unknown vs. negative | 72 months Total sample size: 373 | 0.68 (0.18; 2.59)
Excision volume/local DCIS or invasive carcinoma
Vicini, 2000^174^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by age, calcification, number of slides with DCIS, margin, number of DCIS or COL foci ≤5mm from margin, tumor size, nuclear grade, necrosis, method of detection, and excision volume | LR | <60ml vs. >60ml | 86.4 months Total sample size: 148 | 2.69^*^
Vicini, 2000^174^ Study design: OBS Model: HR of true DCIS or invasive carcinoma recurrence, adjusted by age, calcification, number of slides with DCIS, margin, number of DCIS or COL foci ≤5mm from margin, tumor size, nuclear grade, necrosis, method of detection, and excision volume | LR | <60ml vs. >60ml | 86.4 months Total sample size: 148 | 2.89^*^
Vicini, 2000Vicini, 2000 #983} (local recurrence) Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by age, calcification, number of slides with DCIS, margin, number of DCIS or COL foci ≤5mm from margin, tumor size, nuclear grade, necrosis, method of detection, and re-excision volume | LR | <40ml vs. >40ml | 86.4 months Total sample size: 148 | 2.92^*^
Vicini, 2000^174^ (true recurrence) Study design: OBS Model: HR of true DCIS or invasive carcinoma recurrence, adjusted by age, calcification, number of slides with DCIS, margin, number of DCIS or COL foci ≤5mm from margin, tumor size, nuclear grade, necrosis, method of detection, and re-excision volume | LR | <40ml vs. >40ml | 86.4 months Total sample size: 148 | 15.68 *
10637243 Study design: OBS Model: HR of true invasive carcinoma recurrence, adjusted by age, calcification, number of slides with DCIS, margin, number of DCIS or COL foci ≤5mm from margin, tumor size, nuclear grade, necrosis, method of detection, and re-excision volume | LR | <40ml vs. >40ml | 86.4 months Total sample size: 148 | 6.33 *
Vicini, 2001^180^ Study design: OBS Model: HR of ipsilateral failure, adjusted by age, calcifications, number of slides with DCIS, margin, numbers of DCIS/COL foci ≤5mm from margin, tumor size, nuclear grade, comedonecrosis, and total volume of excision | LR | <60cm3 vs. >60cm3 | 86.4 months Total sample size: 148 | 2.69^*^
Vicini, 2001^180^ Study design: OBS Model: HR of true DCIS or invasive carcinoma recurrence, adjusted by age, calcifications, number of slides with DCIS, margin, numbers of DCIS/COL foci ≤5mm from margin, tumor size, nuclear grade, comedonecrosis, and total volume of excision | LR | <60cm3 vs. >60cm3 | 86.4 months Total sample size: 148 | 2.89^*^
Architecture/any DCIS or invasive carcinoma recurrence
Bijker, 2006^282^ Study design: RCT Model: HR of local DCIS or invasive carcinoma recurrence adjusted by age, method of detection, histology, pathology, margin, and treatment | LR vs. L | Cribriform vs. clinging/microcapillary | 126 months Total sample size: 1,010 | 2.39 (1.41; 4.03)
Bijker, 2006^282^ Study design: RCT Model: HR of local DCIS or invasive carcinoma recurrence adjusted by age, method of detection, histology, pathology, margin, and treatment | LR vs. L | Solid/comedo vs. clinging/microcapillary | 126 months Total sample size: 1,010 | 2.25 (1.21; 4.18)
Fisher, 1999^283^ Study design: RCT Model: RR of local DCIS or invasive carcinoma recurrence, adjusted for treatment | LR vs. L | Solid vs. cribriform | 102 months Total sample size: 818 | 2.41 (1.28; 4.52)
Fisher, 1999^283^ Study design: RCT Model: RR of local DCIS or invasive carcinoma recurrence, adjusted for treatment | LR vs. L | Other vs. cribriform | 102 months Total sample size: 818 | 1.64 (0.91; 2.96)
Smith, 2006^151^ Study design: OBS Model: HR of any second breast cancer event (local DCIS, local invasive carcinoma, and/or subsequent mastectomy) adjusted by age, race, cormobidity, tumor size, histology, grade, treatment, martial status, median income, urban-rural status | LR or L | Papillary vs. DCIS, not specified | 60 months Total sample size: 3,409 | 1.41 (0.98; 2.04)
| LR or L | Cribriform vs. DCIS, not specified | 60 months Total sample size: 3,409 | 0.27 (0.06; 1.11)
| LR or L | DCIS +LCIS vs. DCIS, not specified | 60 months Total sample size: 3,409 | 1.39 (0.69; 2.8)
Architecture/contralateral invasive carcinoma recurrence
Li, 2006^249^ Study design: OBS Model: HR of contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Papillary vs. nos | NA months Total sample size: 37,692 | 1.1 (0.9; 1.5)
Li, 2006^249^ Study design: OBS Model: HR of contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Cribriform vs. nos | NA months Total sample size: 37,692 | 1.2 (0.8; 1.8)
Li, 2006^249^ Study design: OBS Model: HR of contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Solid vs. nos | NA months Total sample size: 37,692 | 1.8 (1; 3.2)
Architecture/local DCIS recurrence
Smith, 2006^151^ Study design: OBS Model: HR of local DCIS recurrence adjusted by age, race, comorbidity, tumor size, histology, grade, treatment, marital status, median income, urban-rural status | LR or L | Papillary vs. DCIS, not specified | 60 months Total sample size: 3,409 | 2 (1.01; 3.99)
Smith, 2006^151^ Study design: OBS Model: HR of local DCIS recurrence adjusted by age, race, comorbidity, tumor size, histology, grade, treatment, marital status, median income, urban-rural status | LR or L | Cribriform vs. DCIS, not specified | 60 months Total sample size: 3,409 | 0.61 (0.08; 4.76)
Smith, 2006^151^ Study design: OBS Model: HR of local DCIS recurrence adjusted by age, race, comorbidity, tumor size, histology, grade, treatment, marital status, median income, urban-rural status | LR or L | DCIS +LCIS vs. DCIS, not specified | 60 months Total sample size: 3,409 | 1.21 (0.28; 5.31)
Architecture/local invasive carcinoma recurrence
Smith, 2006^151^ Study design: OBS Model: HR of local invasive carcinoma recurrence adjusted by age, race, comorbidity, tumor size, histology, grade, treatment, marital status, median income, urban-rural status | LR or L | Papillary vs. DCIS, not specified | 60 months Total sample size: 3,409 | 1.4 (0.81; 2.42)
| LR or L | DCIS +LCIS vs. DCIS, not specified | 60 months Total sample size: 3,409 | 1.24 (0.43; 3.6)
Li, 2006^249^ Study design: OBS Model: HR of local invasive carcinoma recurrence, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Papillary vs. nos | NA months Total sample size: 37,692 | 1.3 (1; 1.7)
Li, 2006^249^ Study design: OBS Model: HR of local invasive carcinoma recurrence, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Cribriform vs. nos | NA months Total sample size: 37,692 | 0.6 (0.3; 1)
Li, 2006^249^ Study design: OBS Model: HR of local invasive carcinoma recurrence, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Solid vs. nos | NA months Total sample size: 37,692 | 1.5 (0.8; 2.9)
Architecture/any invasive carcinoma recurrence
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Papillary vs. nos | NA months Total sample size: 37,692 | 1.2 (1; 1.5)
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Cribriform vs. nos | NA months Total sample size: 37,692 | 0.9 (0.6; 1.2)
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Solid vs. nos | NA months Total sample size: 37,692 | 1.7 (1.1; 2.6)
Comedonecrosis/local DCIS or invasive carcinoma recurrence
Schouten van der Velden, 2007^163^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by age, method of detection, necrosis, treatment, size, and margin | M, MR, L, LR | Comedo vs. noncomedo | 0–189 months Total sample size: 798 | 9.3 (3.3; 25.9)
Ottesen, 2006^240^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by tumor size, necrosis, and nuclear size | L | Comedo vs. non comedo | 81–175 months Total sample size: 168 | 2.3 (1.1; 4.8)
Comedonecrosis/local DCIS recurrence
Smith, 2006^151^ Study design: OBS Model: HR of local DCIS recurrence adjusted by age, race, comorbidity, tumor size, histology, grade, treatment, marital status, median income, urban-rural status | LR or L | Comedo vs. DCIS, not specified | 60 months Total sample size: 3,409 | 1.61 (0.79; 3.26)
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of local DCIS recurrence | M, LR, or L | Yes vs. no or unspecified | 55 months Total sample size: 23,547 | 1.63 (1.11; 2.37)
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of local invasive recurrence | M, LR, or L | Yes vs. no or unspecified | 55 months Total sample size: 23,547 | 1.93 (1.28; 2.91)
Comedonecrosis/local invasive carcinoma recurrence
Smith, 2006^151^ Study design: OBS Model: HR of local invasive carcinoma recurrence adjusted by age, race, comorbidity, tumor size, histology, grade, treatment, marital status, median income, urban-rural status | LR or L | Comedo vs. DCIS, not specified | 60 months Total sample size: 3,409 | 1.35 (0.8; 2.26)
Li, 2006^249^ Study design: OBS Model: HR of local invasive carcinoma recurrence, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Comedo vs. nos | NA months Total sample size: 37,692 | 1.4 (1.1; 1.7)
Comedonecrosis/contralateral invasive carcinoma recurrence
Li, 2006^249^ Study design: OBS Model: HR of contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Comedo vs. nos | NA months Total sample size: 37,692 | 0.9 (0.7; 1)
Comedonecrosis/any invasive carcinoma recurrence
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Comedo vs. nos | NA months Total sample size: 37,692 | 1.1 (0.9; 1.2)
Comedonecrosis/any DCIS or invasive carcinoma recurrence
Smith, 2006^151^ Study design: OBS Model: HR of any second breast cancer event (local DCIS, local invasive carcinoma, and/or subsequent mastectomy) adjusted by age, race, comorbidity, tumor size, histology, grade, treatment, marital status, median income, urban-rural status | LR or L | Comedo vs. DCIS, not specified | 60 months Total sample size: 3,409 | 1.4 (1; 1.97)
Necrosis/local DCIS or invasive carcinoma recurrence
Fisher, 1999^283^ Study design: RCT Model: RR of local DCIS or invasive carcinoma recurrence, adjusted for treatment | LR vs. L | Moderate/marked vs. absent/slight | 102 months Total sample size: 818 | 1.72 (1.23; 2.41)
Fisher, 2001^284^ Study design: RCT Model: RR of local DCIS or invasive carcinoma recurrence in given covariate stratum, adjusted for treatment | LRT vs. LR | Present vs. no | 83 months Total sample size: 1,804 | 1.82 (1.33; 2.47)
Omlin, 2006^237^ Study design: OBS Model: HR of 10-year local DCIS or invasive recurrence, adjusted by age, method of detection, tumor size, necrosis, grade, margin, ER status, and treatment | LR or L | Yes vs. none reported | 1–281 months Total sample size: 373 | 1.28 (0.69; 2.33)
Sahoo, 2005^216^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by margin, age, grade, necrosis, and size | LR | Yes vs. no | 7–191 months Total sample size: 103 | 0.7 (0.16; 3.06)
Warren, 2005^164^ Study design: OBS Model: HR of local DCIS or invasive carcinoma, adjusted for demographic and clinical factors | L, LR, LT, or LRT | Yes vs. no | NA months Total sample size: 1,103 | 0.9 (0.63; 1.3)
Cornfield, 2004^157^ Study design: OBS Model: odds of local DCIS or invasive recurrence, adjusted by tumor size and necrosis | L | 2 or 3 vs. 1 or 0 | 15–201 months Total sample size: 151 | 3.3 (1.5; 7.2)
MacDonald, 2005^191^ Study design: OBS Model: RR of local DCIS or invasive carcinoma recurrence, adjusted by margin, age, grade, tumor size, and necrosis | L | Yes vs. no | NA months Total sample size: 445 | 1.16 (0.52; 2.59)
Necrosis/local DCIS recurrence
Warren, 2005^164^ Study design: OBS Model: OR of local DCIS, adjusted for demographic and clinical factors | L, LR, LT, or LRT | Yes vs. no | NA months Total sample size: 1,103 | 0.8 (0.48; 1.33)
Necrosis/local invasive carcinoma recurrence
Warren, 2005^164^ Study design: OBS Model: OR of local invasive carcinoma, adjusted for demographic and clinical factors | L, LR, LT, or LRT | Yes vs. no | NA months Total sample size: 1,103 | 1.45 (0.83; 2.51)
Age/local DCIS or invasive recurrence
Bijker, 2006^282^ Study design: RCT Model: HR of local DCIS or invasive carcinoma recurrence adjusted by age, method of detection, histology, pathology, margin, and treatment | LR vs. L | Age>40 vs. age ≤40 | 126 months Total sample size: 1,010 | 0.53 (0.31; 0.89)
Fisher, 2001^284^ Study design: RCT Model: RR of local DCIS or invasive carcinoma recurrence in given covariate stratum, adjusted for treatment | LRT vs. LR | Age >50 vs. age ≤49 | 83 months Total sample size: 1,804 | 0.46 (0.34; 0.62)
Omlin, 2006^237^ Study design: OBS Model: HR of 10-year local DCIS or invasive recurrence, adjusted by age, method of detection, tumor size, necrosis, grade, margin, ER status, and treatment | LR or L | 40–45 vs. <39 | 72 months Total sample size: 373 | 0.46 (0.25; 0.83)
Schouten van der Velden, 2007^163^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by age, method of detection, necrosis, treatment, size, and margin | M, MR, L, LR | >60 vs. 40–60 | 59 months Total sample size: 798 | 0.83 (0.5; 1.43)
Schouten van der Velden, 2007^163^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by age, method of detection, necrosis, treatment, size, and margin | M, MR, L, LR | >60 vs. <40 | 59 months Total sample size: 798 | 0.83 (0.18; 3.33)
Meijnen, 2008^211^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by age, method of detection, treatment, margins, and grades | M, LR or L | ≥40 vs. <40 | 80.4 months Total sample size: 504 | 0.12 (0.04; 0.38)
Ben-David, 2007^206^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted in multivariate analysis, unspecified | LR or LRT | >50 vs. ≤50 | 74.4 months Total sample size: 198 | 0.32 (0.11; 0.91)
Warren, 2005^164^ Study design: OBS Model: HR of local DCIS or invasive carcinoma, adjusted for demographic and clinical factors | L, LR, LT, or LRT | 51–64 vs. <51 | 91 months Total sample size: 1,103 | 0.72 (0.47; 1.08)
Warren, 2005^164^ Study design: OBS Model: HR of local DCIS or invasive carcinoma, adjusted for demographic and clinical factors | L, LR, LT, or LRT | ≥65 vs. <51 | 91 months Total sample size: 1,103 | 0.79 (0.53; 1.18)
Cutuli, 2001^160^ Study design: OBS Model: HR of local recurrence (not specific) adjusted by treatment, age, method of detection, margin, and family history | LR | ≥60 vs. 40–59 | 91 months Total sample size: 716 | 0.67 (0.47; 0.94)
Cutuli, 2001^160^ Study design: OBS Model: HR of local recurrence (not specific) adjusted by treatment, age, method of detection, margin, and family history | LR | ≥60 vs. <40 | 91 months Total sample size: 716 | 0.44 (0.22; 0.89)
Solin, 2005^152^ Study design: OBS Model: HR of local recurrence (not specified) adjusted by age, margin, mammographic findings, institution, date, location of primary tumor, and irradiation dose | LR | Age 50–59 vs. age ≤39 | 102 months Total sample size: 1,003 | 0.36 *
Solin, 2005^152^ Study design: OBS Model: HR of local recurrence (not specified) adjusted by age, margin, mammographic findings, institution, date, location of primary tumor, and irradiation dose | LR | Age ≥60 vs. age ≤39 | 102 months Total sample size: 1,003 | 0.23 *
Kerlikowske, 2003^166^ Study design: OBS Model: OR of ipsilateral DCIS or invasive carcinoma recurrence, adjusted by age, tumor size, margin, nuclear grade, quantity of necrosis, and cell polarity | L | >50 vs. 40–49 | 77.9 months Total sample size: 1,036 | 0.71 (0.42; 1.11)
Rudloff, 2009^257^ Study design: OBS Model: HR of local DCIS or invasive recurrence, adjusted by age, method of detection, treatment, and lobular neoplasia | LR or L | ≥45 vs. <45 | 132 months Total sample size: 294 | 0.5 (0.26; 0.97)
Age/local DCIS recurrence
Kerlikowske, 2003^166^ Study design: OBS Model: OR of ipsilateral DCIS recurrence, adjusted by age, tumor size, margin, nuclear grade, and cell polarity | L | >50 vs. 40–49 | 77.9 months Total sample size: 1,036 | 0.43 (0.21; 0.91)
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of local DCIS recurrence | M, LR, or L | <40 vs. 50–65 | 55 months Total sample size: 23,547 | 2.35 (1.23; 4.51)
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of local DCIS recurrence | M, LR, or L | >65 vs. 50–65 | 55 months Total sample size: 23,547 | 1.18 (0.78; 1.79)
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of local DCIS recurrence | M, LR, or L | 40–49 vs. 50–65 | 55 months Total sample size: 23,547 | 1.14 (0.7; 1.85)
Age/local invasive recurrence
Li, 2006^249^ Study design: OBS Model: HR of local invasive carcinoma recurrence, adjusted by year, registry, race, and surgery/radiation | M, LR, or L | 50–59 vs. 20–49 | NA months Total sample size: 37,692 | 0.71 (0.56; 0.91)
Li, 2006^249^ Study design: OBS Model: HR of local invasive carcinoma recurrence, adjusted by year, registry, race, and surgery/radiation | M, LR, or L | 60–69 vs. 50–59 | NA months Total sample size: 37,692 | 1 (0.8; 1.3)
Li, 2006^249^ Study design: OBS Model: HR of local invasive carcinoma recurrence, adjusted by year, registry, race, and surgery/radiation | M, LR, or L | ≥70 vs. 50–59 | NA months Total sample size: 37,692 | 1.1 (0.8; 1.4)
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of local invasive recurrence | M, LR, or L | <40 vs. 50–65 | 55 months Total sample size: 23,547 | 3.68 (1.79; 7.58)
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of local invasive recurrence | M, LR, or L | >65 vs. 50–65 | 55 months Total sample size: 23,547 | 0.99 (0.6; 1.63)
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of local invasive recurrence | M, LR, or L | 40–49 vs. 50–65 | 55 months Total sample size: 23,547 | 2.22 (1.36; 3.63)
Age/regional and distant invasive
Innos, 2008^259^Study design: OBS Model: Poisson-regression derived incidence rate ratio of regional and distant invasive | M, LR, or L | <40 vs. 50–64 | 55 months Total sample size: 23,547 | 5.43 (1.34; 21.91)
Innos, 2008^259^Study design: OBS Model: Poisson-regression derived incidence rate ratio of regional and distant invasive | M, LR, or L | 40–49 vs. 50–64 | 55 months Total sample size: 23,547 | 3.06 (1.11; 8.46)
Age as continuous variable/local DCIS or invasive recurrence
Vargas, 2005^181^ Study design: OBS Model: HR of ipsilateral failure, adjusted by age, ahole breast radiation, and margin | LR or L | As continuous variable | 84 months Total sample size: 410 | 0.92 *
Vargas, 2005^181^ Study design: OBS Model: HR of ipsilateral failure, adjusted by age, preradiation mammogram, mass in mammogram, boost energy, and margin | LR or L | As continuous variable | 84 months Total sample size: 410 | 0.94 *
Vargas, 2005^181^ Study design: OBS Model: HR of ipsilateral failure, adjusted by age, preradiation mammogram, mass in mammogram, boost energy, and residual DCIS at re-excision | LR or L | As continuous variable | 84 months Total sample size: 410 | 0.96 *
Vicini, 2001^180^ Study design: OBS Model: HR of ipsilateral failure, adjusted by age, calcifications, number of slides with DCIS, margin, numbers of DCIS/COL foci ≤5mm from margin, tumor size, nuclear grade, comedonecrosis, and total volume of excision | LR | As continuous variable | 86.4 months Total sample size: 148 | 0.96^*^
Vicini, 2001^180^ Study design: OBS Model: HR of true failure, adjusted by age, calcifications, number of slides with DCIS, margin, numbers of DCIS/COL foci ≤5mm from margin, tumor size, nuclear grade, comedonecrosis, and total volume of excision | LR | As continuous variable | 86.4 months Total sample size: 148 | 0.93 *
Vicini, 2001^180^ Study design: OBS Model: HR of ipsilateral failure, adjusted by age, calcifications, number of slides with DCIS/total volume, margin, numbers of DCIS/COL foci ≤5mm from margin, tumor size, nuclear grade, and comedonecrosis | LR | As continuous variable | 86.4 months Total sample size: 148 | 0.97^*^
Vicini, 2001^180^ Study design: OBS Model: HR of true failure, adjusted by age, calcifications, number of slides with DCIS/total volume, margin, numbers of DCIS/COL foci ≤5mm from margin, tumor size, nuclear grade, and comedonecrosis | LR | As continuous variable | 86.4 months Total sample size: 148 | 0.95 *
Vicini, 2000^174^ (local recurrence) Study design: OBS Model: HR of true DCIS or invasive carcinoma recurrence, adjusted by age, calcification, number of slides with DCIS, margin, number of DCIS or COL foci ≤5mm from margin, tumor size, nuclear grade, necrosis, method of detection, and excision volume | LR | As continuous variable | 86.4 months Total sample size: 148 | 0.93 *
Vicini, 2000^174^ (true recurrence) Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by age, calcification, number of slides with DCIS, margin, number of DCIS or COL foci ≤5mm from margin, tumor size, nuclear grade, necrosis, method of detection, and excision volume | LR | As continuous variable | 86.4 months Total sample size: 148 | 0.96^*^
Vicini, 2000^174^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by age, calcification, number of slides with DCIS, margin, number of DCIS or COL foci ≤5mm from margin, tumor size, nuclear grade, necrosis, method of detection, and re-excision volume | LR | As continuous variable | 86.4 months Total sample size: 148 | 0.94^*^
Goldstein, 2000^209^ Study design: OBS Model: HR of true DCIS or invasive carcinoma recurrence, adjusted by age, number of slides with DCIS, number of DCIS or TDLU within 4.2 mm of final margin, nuclear grade, microcalcification, and tumor size | LR | As continuous variable | 84 months Total sample size: 132 | 0.89 *
Age as continuous variable/local DCIS recurrence
Smith, 2006^151^ Study design: OBS Model: HR of local DCIS recurrence adjusted by age, race, comorbidity, tumor size, histology, grade, treatment, marital status, median income, urban-rural status | LR | Age as continuous variable | 60 months Total sample size: 3,409 | 0.94 (0.89; 0.99)
Age as continuous variable/local invasive recurrence
Smith, 2006^151^ Study design: OBS Model: HR of local invasive carcinoma recurrence adjusted by age, race, comorbidity, tumor size, histology, grade, treatment, marital status, median income, urban-rural status | LR | Age as continuous variable | 60 months Total sample size: 3,409 | 1 (0.96; 1.03)
Age as continuous variable/any DCIS or invasive recurrence
Smith, 2006^151^ Study design: OBS Model: HR of any second breast cancer event (local DCIS, local invasive carcinoma, and/or subsequent mastectomy) adjusted by age, race, comorbidity, tumor size, histology, grade, treatment, marital status, median income, urban-rural status | LR | Age as continuous variable | 60 months Total sample size: 3,409 | 0.97 (0.95; 1)
Age/contralateral DCIS
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of contralateral DCIS | M, LR, or L | <40 vs. 50–65 | 55 months Total sample size: 23,547 | 0.36 (0.15; 0.88)
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of contralateral DCIS | M, LR, or L | >65 vs. 50–65 | 55 months Total sample size: 23,547 | 0.87 (0.64; 1.18)
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of contralateral DCIS | M, LR, or L | 40–49 vs. 50–65 | 55 months Total sample size: 23,547 | 1.06 (0.76; 1.48)
Age/contralateral invasive
Li, 2006^249^ Study design: OBS Model: HR of contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | 60–69 vs. 50–59 | NA months Total sample size: 37,692 | 1.3 (1; 1.6)
Li, 2006^249^ Study design: OBS Model: HR of contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | ≥70 vs. 50–59 | NA months Total sample size: 37,692 | 1.5 (1.2; 1.8)
Li, 2006^249^ Study design: OBS Model: HR of contralateral invasive carcinoma, adjusted by year, registry, race, and surgery/radiation | M, LR, or L | 50–59 vs. 20–49 | NA months Total sample size: 37,692 | 1.11 (0.91; 1.43)
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of contralateral invasive | M, LR, or L | <40 vs. 50–65 | 55 months Total sample size: 23,547 | 1.12 (0.76; 1.66)
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of contralateral invasive | M, LR, or L | >65 vs. 50–65 | 55 months Total sample size: 23,547 | 1.35 (1.11; 1.66)
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of contralateral invasive | M, LR, or L | 40–49 vs. 50–65 | 55 months Total sample size: 23,547 | 0.86 (0.66; 1.11)
Age/any DCIS or invasive recurrence
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma, adjusted by year, registry, race, and surgery/radiation | M, LR, or L | 50–59 vs. 20–49 | NA months Total sample size: 37,692 | 0.91 (0.77; 1)
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma, adjusted by year, registry, race, and surgery/radiation | M, LR, or L | 60–69 vs. 50–59 | NA months Total sample size: 37,692 | 1.2 (1; 1.3)
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma, adjusted by year, registry, race, and surgery/radiation | M, LR, or L | ≥70 vs. 50–59 | NA months Total sample size: 37,692 | 1.3 (1.1; 1.5)
Age/any invasive carcinoma, stage I
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma stage I, adjusted by year, registry, race, and surgery/radiation | M, LR, or L | 50–59 vs. 20–49 | NA months Total sample size: 37,692 | 1 (0.82; 1.25)
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma stage I, adjusted by year, registry, race, and surgery/radiation | M, LR, or L | 60–69 vs. 50–59 | NA months Total sample size: 37,692 | 1.3 (1.1; 1.6)
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma stage I, adjusted by year, registry, race, and surgery/radiation | M, LR, or L | ≥70 vs. 50–59 | NA months Total sample size: 37,692 | 1.4 (1.2; 1.7)
Age/any invasive carcinoma, stage II
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma stage II, adjusted by year, registry, race, and surgery/radiation | M, LR, or L | 50–59 vs. 20–49 | NA months Total sample size: 37,692 | 0.71 (0.53; 0.91)
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma stage II, adjusted by year, registry, race, and surgery/radiation | M, LR, or L | 60–69 vs. 50–59 | NA months Total sample size: 37,692 | 1.1 (0.8; 1.5)
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma stage II, adjusted by year, registry, race, and surgery/radiation | M, LR, or L | ≥70 vs. 50–59 | NA months Total sample size: 37,692 | 1.1 (0.8; 1.5)
Age/any invasive carcinoma, stage III/IV
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma stage III/IV, adjusted by year, registry, race, and surgery/radiation | M, LR, or L | 50–59 vs. 20–49 | NA months Total sample size: 37,692 | 0.63 (0.38; 1)
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma stage III/IV, adjusted by year, registry, race, and surgery/radiation | M, LR, or L | 60–69 vs. 50–59 | NA months Total sample size: 37,692 | 0.9 (0.5; 1.6)
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma stage III/IV, adjusted by year, registry, race, and surgery/radiation | M, LR, or L | ≥70 vs. 50–59 | NA months Total sample size: 37,692 | 0.9 (0.5; 1.5)
Alcohol consumption/local DCIS or invasive carcinoma recurrence
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | 1–2 drinks per week vs. no | 62 months Total sample size: 709 | 0.7 (0.4; 1.3)
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | 3–7 drinks per week vs. no | 62 months Total sample size: 709 | 0.9 (0.4; 1.7)
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | ≥8 drinks per week vs. no | 62 months Total sample size: 709 | 0.5 (0.2; 1.3)
Alcohol consumption/local invasive carcinoma recurrence
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by followup time and age | LR or L | 1–2 drinks per week vs. no | 62 months Total sample size: 709 | 0.6 (0.3; 1.3)
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by followup time and age | LR or L | 3–7 drinks per week vs. no | 62 months Total sample size: 709 | 0.8 (0.3; 2)
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by followup time and age | LR or L | ≥8 drinks per week vs. no | 62 months Total sample size: 709 | 0.5 (0.1; 1.9)
Patient’s weight/adverse effect
Ben-David, 2007^206^ Study design: OBS Model: OR of grade 2 maximal acute toxicity, adjusted, not specified | LR or LRT | >200 lb vs. ≤200 lb | 74.4 months Total sample size: 198 | 9 (2.6; 31.7)
Race/local DCIS or invasive carcinoma recurrence
Smith, 2006^165^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by age, race, year of diagnosis, site, prognostic score, and treatment. | M, LR, L | Non white vs. white | 28.8 months Total sample size: 14,202 | 0.97 (0.66; 1.43)
Warren, 2005^164^ Study design: OBS Model: HR of local DCIS or invasive carcinoma, adjusted for demographic and clinical factors | L, LR, LT, or LRT | Black vs. white | 91 months Total sample size: 1,103 | 1.12 (0.61; 2.06)
Warren, 2005^164^ Study design: OBS Model: HR of local DCIS or invasive carcinoma, adjusted for demographic and clinical factors | L, LR, LT, or LRT | Other vs. white | 91 months Total sample size: 1,103 | 0.93 (0.45; 1.93)
Race/local DCIS recurrence
Smtih, 2006^151^ Study design: OBS Model: HR of local DCIS recurrence adjusted by age, race, comorbidity, tumor size, histology, grade, treatment, marital status, median income, urban-rural status | LR or L | Black vs. white | 60 months Total sample size: 3,409 | 2.17 (0.87; 5.43)
Smtih, 2006^151^ Study design: OBS Model: HR of local DCIS recurrence adjusted by age, race, comorbidity, tumor size, histology, grade, treatment, marital status, median income, urban-rural status | LR or L | White hispanic vs. white | 60 months Total sample size: 3,409 | 0.6 (0.08; 4.71)
Warren, 2005^164^ Study design: OBS Model: OR of local DCIS, adjusted for demographic and clinical factors | L, LR, LT, or LRT | Black vs. white | 91 months Total sample size: 1,103 | 1.12 (0.49; 2.59)
Warren, 2005^164^ Study design: OBS Model: OR of local DCIS, adjusted for demographic and clinical factors | L, LR, LT, or LRT | Other vs. white | 91 months Total sample size: 1,103 | 0.79 (0.27; 2.26)
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of local DCIS recurrence | M, LR, or L | Asian-Pacific vs. white | 55 months Total sample size: 23,547 | 1 (0.5; 1.99)
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of local DCIS recurrence | M, LR, or L | Black vs. white | 55 months Total sample size: 23,547 | 1.35 (0.7; 2.59)
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of local DCIS recurrence | M, LR, or L | Hispanic vs. white | 55 months Total sample size: 23,547 | 0.89 (0.48; 1.66)
Race/local invasive recurrence
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of local invasive recurrence | M, LR, or L | Asian-Pacific vs. white | 55 months Total sample size: 23,547 | 1.54 (0.86; 2.75)
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of local invasive recurrence | M, LR, or L | Black vs. white | 55 months Total sample size: 23,547 | 1.91 (1.01; 3.59)
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of local invasive recurrence | M, LR, or L | Hispanic vs. white | 55 months Total sample size: 23,547 | 0.78 (0.37; 1.61)
Race/local invasive carcinoma recurrence
Smith, 2006^151^ Study design: OBS Model: HR of local invasive carcinoma recurrence adjusted by age, race, comorbidity, tumor size, histology, grade, treatment, marital status, median income, urban-rural status | LR or L | Black vs. white | 60 months Total sample size: 3,409 | 1.4 (0.64; 3.23)
| LR or L | Asian-Pacific Islander vs. white | 60 months Total sample size: 3,409 | 0.95 (0.31; 2.91)
| LR or L | White hispanic vs. white | 60 months Total sample size: 3,409 | 0.28 (0.04; 2.11)
Li, 2006^249^ Study design: OBS Model: HR of local invasive carcinoma recurrence, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Black vs. white | NA months Total sample size: 37,692 | 1.5 (1.2; 2)
Li, 2006^249^ Study design: OBS Model: HR of local invasive carcinoma recurrence, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Asian vs. white | NA months Total sample size: 37,692 | 1.2 (0.9; 1.6)
Li, 2006^249^ Study design: OBS Model: HR of local invasive carcinoma recurrence, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Hispanic vs. white | NA months Total sample size: 37,692 | 1.2 (0.8; 1.7)
Warren, 2005^164^ Study design: OBS Model: OR of local invasive carcinoma, adjusted for demographic and clinical factors | L, LR, LT, or LRT | Black vs. white | 91 months Total sample size: 1,103 | 1.05 (0.4; 2.77)
Warren, 2005^164^ Study design: OBS Model: OR of local invasive carcinoma, adjusted for demographic and clinical factors | L, LR, LT, or LRT | Other vs. white | 91 months Total sample size: 1,103 | 1.08 (0.37; 3.17)
Race/regional and distant invasive
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of regional and distant invasive | M, LR, or L | Black vs. white | 55 months Total sample size: 23,547 | 4.82 (1.71; 13.59)
Race/contralateral DCIS
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of contralateral DCIS | M, LR, or L | Asian-pacific vs. white | 55 months Total sample size: 23,547 | 1.28 (0.82; 2)
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of contralateral DCIS | M, LR, or L | Black vs. white | 55 months Total sample size: 23,547 | 0.72 (0.37; 1.41)
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of contralateral DCIS | M, LR, or L | Hispanic vs. white | 55 months Total sample size: 23,547 | 0.83 (0.51; 1.37)
Race/contralateral invasive
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of contralateral invasive | M, LR, or L | Asian-Pacific vs. white | 55 months Total sample size: 23,547 | 1.2 (0.87; 1.67)
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of contralateral invasive | M, LR, or L | Black vs. white | 55 months Total sample size: 23,547 | 1.2 (0.84; 1.72)
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of contralateral invasive | M, LR, or L | Hispanic vs. white | 55 months Total sample size: 23,547 | 0.64 (0.44; 0.95)
Race/contralateral invasive carcinoma
Li, 2006^249^ Study design: OBS Model: HR of contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Black vs. white | NA months Total sample size: 37,692 | 1.3 (1; 1.7)
Li, 2006^249^ Study design: OBS Model: HR of contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Asian vs. white | NA months Total sample size: 37,692 | 1.2 (0.9; 1.6)
Li, 2006^249^ Study design: OBS Model: HR of contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Hispanic vs. white | NA months Total sample size: 37,692 | 0.7 (0.5; 1.1)
Race/any DCIS or invasive carcinoma
Smith, 2006^151^ Study design: OBS Model: HR of any second breast cancer event (local DCIS, local invasive carcinoma, and/or subsequent mastectomy) adjusted by age, race, comorbidity, tumor size, histology, grade, treatment, marital status, median income, urban-rural status | LR or L | Black vs. white | 60 months Total sample size: 3,409 | 1.39 (0.85; 2.29)
| LR or L | Asian-Pacific Islander vs. white | 60 months Total sample size: 3,409 | 0.46 (0.18; 1.22)
| LR or L | White hispanic vs. white | 60 months Total sample size: 3,409 | 1.13 (0.56; 2.28)
Race/any invasive carcinoma
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Black vs. white | NA months Total sample size: 37,692 | 1.4 (1.2; 1.7)
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Asian vs. white | NA months Total sample size: 37,692 | 1.1 (0.9; 1.4)
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Hispanic vs. white | NA months Total sample size: 37,692 | 1 (0.7; 1.3)
Race/any invasive carcinoma, stage I
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma stage I, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Black vs. white | NA months Total sample size: 37,692 | 1.2 (0.9; 1.5)
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma stage I, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Asian vs. white | NA months Total sample size: 37,692 | 1.1 (0.8; 1.5)
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma stage I, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Hispanic vs. white | NA months Total sample size: 37,692 | 0.8 (0.6; 1.2)
Race/any invasive carcinoma, stage II
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma stage II, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Black vs. white | NA months Total sample size: 37,692 | 1.7 (1.2; 2.3)
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma stage II, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Asian vs. white | NA months Total sample size: 37,692 | 1.3 (0.9; 1.9)
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma stage II, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Hispanic vs. white | NA months Total sample size: 37,692 | 1.2 (0.7; 1.9)
Race/any invasive carcinoma, stage III/IV
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma stage III/IV, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Black vs. white | NA months Total sample size: 37,692 | 2.7 (1.7; 4.4)
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma stage III/IV, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Asian vs. white | NA months Total sample size: 37,692 | 0.7 (0.3; 1.7)
Li, 2006^249^ Study design: OBS Model: HR of local or contralateral invasive carcinoma stage III/IV, adjusted by age, year, registry, and surgery/radiation | M, LR, or L | Hispanic vs. white | NA months Total sample size: 37,692 | 2.3 (1.1; 4.8)
Race/mortality
Joslyn, 2006^161^ Study design: OBS Model: RR of mortality, adjusted by surgery, age, site, race, and radiation | M, MR, L, LR, R | Black vs. white | NA months Total sample size: 41,245 | 1.35 (1.12; 1.62)
Joslyn, 2006^161^ Study design: OBS Model: RR of mortality, adjusted by surgery, age, site, race, and radiation | M, MR, L, LR, R | American Indian vs. white | NA months Total sample size: 41,245 | 0.95 (0.24; 3.83)
Joslyn, 2006^161^ Study design: OBS Model: RR of mortality, adjusted by surgery, age, site, race, and radiation | M, MR, L, LR, R | Asian vs. white | NA months Total sample size: 41,245 | 0.74 (0.51; 1.07)
Joslyn, 2006^161^ Study design: OBS Model: RR of mortality, adjusted by surgery, age, site, race, and radiation | M, MR, L, LR, R | Other vs. white | NA months Total sample size: 41,245 | 1.15 (0.29; 4.61)
BMI/local DCIS or invasive carcinoma recurrence
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | 22.9–27.7 vs. <22.9 | 62 months Total sample size: 709 | 1.2 (0.7; 2.1)
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | 27.8–30.7 vs. <22.9 | 62 months Total sample size: 709 | 1.4 (0.7; 3.1)
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | >30.8 vs. <22.9 | 62 months Total sample size: 709 | 2.3 (1.1; 4.8)
BMI/local invasive carcinoma recurrence
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by followup time and age | LR or L | 22.9–27.7 vs. <22.9 | 62 months Total sample size: 709 | 1.6 (0.7; 3.8)
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by followup time and age | LR or L | 27.8–30.7 vs. <22.9 | 62 months Total sample size: 709 | 2.8 (1; 8.1)
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by followup time and age | LR or L | >30.8 vs. <22.9 | 62 months Total sample size: 709 | 3.5 (1.1; 10.8)
Calcification/local DCIS or invasive carcinoma recurrence
Vicini, 2000^174^ (local recurrence) Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by age, calcification, number of slides with DCIS, margin, number of DCIS or COL foci ≤5mm from margin, tumor size, nuclear grade, necrosis, method of detection, and excision volume | LR | No vs. yes | 86.4 months Total sample size: 148 | 3.57 *
Goldstein, 2000^209^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by age, number of slides with DCIS, number of DCIS or TDLU within 4.2 mm of final margin, nuclear grade, microcalcification, and tumor size | LR | No vs. yes | 84 months Total sample size: 132 | 4.55 *
Goldstein, 2000^209^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by age, number of slides with DCIS, margin, tumor size, nuclear grade, necrosis, and number of DCIS and COL foci ≤5mm from the margin | LR | No vs. yes | 84 months Total sample size: 132 | 4.55 *
Vicini, 2000^174^ (true recurrence) Study design: OBS Model: HR of true DCIS or invasive carcinoma recurrence, adjusted by age, calcification, number of slides with DCIS, margin, number of DCIS or COL foci ≤5mm from margin, tumor size, nuclear grade, necrosis, method of detection, and excision volume | LR | No vs. yes | 86.4 months Total sample size: 148 | 6.57 *
Vicini, 2000^174^ Study design: OBS Model: HR of true DCIS or invasive carcinoma recurrence, adjusted by age, calcification, number of slides with DCIS, margin, number of DCIS or COL foci ≤5mm from margin, tumor size, nuclear grade, necrosis, method of detection, and re-excision volume | LR | No vs. yes | 86.4 months Total sample size: 148 | 4.76 *
Goldstein, 2000^209^ Study design: OBS Model: HR of true DCIS or invasive carcinoma recurrence, adjusted by age, number of slides with DCIS, number of DCIS or TDLU within 4.2 mm of final margin, nuclear grade, microcalcification, and tumor size | LR | No vs. yes | 84 months Total sample size: 132 | 5 *
Kestin, 2000^171^ Study design: OBS Model: HR of true DCIS or invasive carcinoma recurrence, adjusted by age, number of slides with DCIS, margin, tumor size, nuclear grade, necrosis, and number of DCIS and COL foci ≤5mm from the margin | LR | No vs. yes | 84 months Total sample size: 132 | 5 *
Vicini, 2001^180^ Study design: OBS Model: HR of ipsilateral failure, adjusted by age, calcifications, number of slides with DCIS, margin, numbers of DCIS/COL foci ≤5mm from margin, tumor size, nuclear grade, comedonecrosis, and total volume of excision | LR | No vs. yes | 86.4 months Total sample size: 148 | 3.57 *
Vicini, 2001^180^ Study design: OBS Model: HR of true DCIS or invasive carcinoma recurrence, adjusted by age, calcifications, number of slides with DCIS/total volume, margin, numbers of DCIS/COL foci ≤5mm from margin, tumor size, nuclear grade, and comedonecrosis | LR | No vs. yes | 86.4 months Total sample size: 148 | 5 *
Vicini, 2001^180^ Study design: OBS Model: HR of true DCIS or invasive carcinoma recurrence, adjusted by age, calcifications, number of slides with DCIS, margin, numbers of DCIS/COL foci ≤5mm from margin, tumor size, nuclear grade, comedonecrosis, and total volume of excision | LR | No vs. yes | 86.4 months Total sample size: 148 | 3.57 *
Comorbidity/local DCIS or invasive carcinoma recurrence
Warren, 2005^164^ Study design: OBS Model: HR of local DCIS or invasive carcinoma, adjusted for demographic and clinical factors | L, LR, LT, or LRT | ≥ 1 vs. =0 | 91 months Total sample size: 1,103 | 1.62 (1.02; 2.57)
Comorbidity/local DCIS recurrence
Warren, 2005^164^ Study design: OBS Model: OR of local DCIS, adjusted for demographic and clinical factors | L, LR, LT, or LRT | ≥ 1 vs. =0 | 91 months Total sample size: 1,103 | 2.02 (1.08; 3.77)
Smith, 2006^151^ Study design: OBS Model: HR of local DCIS recurrence adjusted by age, race, comorbidity, tumor size, histology, grade, treatment, marital status, median income, urban-rural status | LR or L | 1 vs. 0 | 60 months Total sample size: 3,409 | 1.17 (0.6; 2.28)
Smith, 2006^151^ Study design: OBS Model: HR of local DCIS recurrence adjusted by age, race, comorbidity, tumor size, histology, grade, treatment, marital status, median income, urban-rural status | LR or L | 2–9 vs. 0 | 60 months Total sample size: 3,409 | 0.68 (0.2; 2.3)
Comorbidity/local invasive carcinoma recurrence
Warren, 2005^164^ Study design: OBS Model: OR of local invasive carcinoma, adjusted for demographic and clinical factors | L, LR, LT, or LRT | ≥ 1 vs. =0 | 91 months Total sample size: 1,103 | 1.12 (0.51; 2.49)
Smith, 2006^151^ Study design: OBS Model: HR of local invasive carcinoma recurrence adjusted by age, race, comorbidity, tumor size, histology, grade, treatment, marital status, median income, urban-rural status | LR or L | 1 vs. 0 | 60 months Total sample size: 3,409 | 1.4 (0.86; 2.27)
| LR or L | 2–9 vs. 0 | 60 months Total sample size: 3,409 | 1.11 (0.51; 2.4)
Comorbidity/any DCIS or invasive carcinoma recurrence
Smith, 2006^151^ Study design: OBS Model: HR of any second breast cancer event (local DCIS, local invasive carcinoma, and/or subsequent mastectomy) adjusted by age, race, comorbidity, tumor size, histology, grade, treatment, marital status, median income, urban-rural status | LR or L | 1 vs. 0 | 60 months Total sample size: 3,409 | 1.2 (0.86; 1.62)
| LR or L | 2–9 vs. 0 | 60 months Total sample size: 3,409 | 1.1 (0.7; 1.8)
Family history/local DCIS or invasive carcinoma recurrence
Ben-David, 2007^206^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted in multivariate analysis, unspecified | LR or LRT | Yes vs. no | 74.4 months Total sample size: 198 | 3.08 (1.04; 9.1)
Cutuli, 2001^160^ Study design: OBS Model: HR of local recurrence (not specific) adjusted by treatment, age, method of detection, margin, and family history | LR or L | Yes vs. no | 91 months Total sample size: 716 | 0.84 (0.51; 1.37)
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | Relatives ≥ 50 years vs. no | 62 months Total sample size: 709 | 0.9 (0.5; 1.7)
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | Relatives <50 years vs. no | 62 months Total sample size: 709 | 1.6 (0.7; 3.3)
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | Age <50 and relatives <50 years vs. no | 62 months Total sample size: 709 | 2.4 (0.8; 7)
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | Age >50 and relatives <50 years vs. no | 62 months Total sample size: 709 | 1.2 (0.4; 3.4)
Family history/local invasive carcinoma recurrence
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by followup time and age | LR or L | Relatives ≥ 50 years vs. no | 62 months Total sample size: 709 | 0.7 (0.2; 1.9)
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by followup time and age | LR or L | Relatives <50 years vs. no | 62 months Total sample size: 709 | 1.7 (0.6; 5)
Age of first birth/local DCIS or invasive carcinoma recurrence
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | 20–29 vs. <20 | 62 months Total sample size: 709 | 1.7 (0.9; 3.6)
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | ≥ 30 vs. <20 | 62 months Total sample size: 709 | 0.7 (0.2; 2.3)
Age of first birth/local DCIS recurrence
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by followup time and age | LR or L | 20–29 vs. <20 | 62 months Total sample size: 709 | 2.1 (0.7; 6.1)
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by followup time and age | LR or L | ≥ 30 vs. <20 | 62 months Total sample size: 709 | 0.7 (0.1; 4)
Focality/local DCIS or invasive carcinoma recurrence
Fisher, 1999^283^ Study design: RCT Model: RR of local DCIS or invasive carcinoma recurrence, adjusted for treatment | LR vs. L | Multifocal vs. unifocal | 102 months Total sample size: 818 | 1.55 (1.07; 2.26)
Rakovitch, 2007^243^ Study design: OBS Model: HR of local DCIS or invasive recurrence, adjusted by radiation, nuclear grade, multifocality, and margin | LR or L | Yes vs. no | NA months Total sample size: 310 | 1.8 (1.15; 2.8)
Rakovitch, 2007^243^ Study design: OBS Model: HR of local DCIS or invasive recurrence, adjusted by radiation, nuclear grade, multifocality, and margin, in negative margin cases | LR or L | Yes vs. no | NA months Total sample size: 310 | 1.97 (1.23; 3.15)
Growth pattern/local DCIS or invasive carcinoma recurrence
Ringberg, 2001^187^ Study design: OBS Model: RR of local DCIS or invasive carcinoma recurrence free interval, adjusted by CBI-7, grade, and growth pattern | L | Diffuse vs. not diffuse | 62 months Total sample size: 121 | 1.5 (0.6; 3.6)
Idvall, 2003^232^ Study design: OBS Model: RR of local DCIS or invasive carcinoma recurrence free interval, adjusted by mitotic frequency, grade, and growth pattern | L | Diffuse vs. not diffuse | NA months Total sample size: 121 | 1.8 (0.9; 3.8)
Idvall, 2003^232^ Study design: OBS Model: RR of local DCIS or invasive carcinoma recurrence free interval, adjusted by polarisation, grade, and growth pattern | L | Diffuse vs. not diffuse | NA months Total sample size: 121 | 1.7 (0.8; 3.6)
HRT/local DCIS or invasive carcinoma recurrence
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by follow-up time and age | LR or L | <2 years vs. no | 62 months Total sample size: 709 | 1.2 (0.4; 3)
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by follow-up time and age | LR or L | ≥ 2 years vs. no | 62 months Total sample size: 709 | 1.8 (0.7; 5)
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by follow-up time and age | LR or L | ≥ 2 years estrogen alone vs. no | 62 months Total sample size: 709 | 2.1 (0.7; 6.1)
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by follow-up time and age | LR or L | ≥ 2 years estrogen plus progestin vs. no | 62 months Total sample size: 709 | 2.6 (0.3; 20.3)
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by follow-up time and age | LR or L | Estrogen vs. no | 62 months Total sample size: 709 | 1.2 (0.6; 2.4)
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by follow-up time and age | LR or L | Estrogen + progestin vs. no | 62 months Total sample size: 709 | 0.7 (0.2; 2.6)
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by follow-up time and age | LR or L | <10 years vs. no | 62 months Total sample size: 709 | 1.1 (0.5; 2.4)
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by follow-up time and age | LR or L | ≥ 10 years vs. no | 62 months Total sample size: 709 | 1.1 (0.5; 2.6)
HRT/local invasive carcinoma recurrence
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by follow-up time and age | LR or L | <2 years vs. no | 62 months Total sample size: 709 | 1.7 (0.4; 8.2)
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by follow-up time and age | LR or L | ≥ 2 years vs. no | 62 months Total sample size: 709 | 2.4 (0.6; 9.6)
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by follow-up time and age | LR or L | Estrogen vs. no | 62 months Total sample size: 709 | 0.9 (0.3; 2.8)
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by follow-up time and age | LR or L | Estrogen + progestin vs. no | 62 months Total sample size: 709 | 1.4 (0.3; 7.2)
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by follow-up time and age | LR or L | <10 years vs. no | 62 months Total sample size: 709 | 1.3 (0.4; 4)
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by follow-up time and age | LR or L | ≥ 10 years vs. no | 62 months Total sample size: 709 | 0.7 (0.2; 2.9)
Marital status/local DCIS or invasive carcinoma recurrence
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | Formerly married vs. married | 62 months Total sample size: 709 | 1.4 (0.8; 2.5)
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | Single vs. married | 62 months Total sample size: 709 | 2.2 (1; 4.9)
Warren, 2005^164^ Study design: OBS Model: HR of local DCIS or invasive carcinoma, adjusted for demographic and clinical factors | L, LR, LT, or LRT | Unmarried vs. married | 91 months Total sample size: 1,103 | 1.52 (1.08; 2.13)
Warren, 2005^164^ Study design: OBS Model: HR of local DCIS or invasive carcinoma, adjusted for demographic and clinical factors | L, LR, LT, or LRT | Unknown vs. married | 91 months Total sample size: 1,103 | 0.77 (0.28; 2.15)
Marital status/local DCIS recurrence
Warren, 2005^164^ Study design: OBS Model: OR of local DCIS, adjusted for demographic and clinical factors | L, LR, LT, or LRT | Unmarried vs. married | 91 months Total sample size: 1,103 | 1.13 (0.7; 1.82)
Warren, 2005^164^ Study design: OBS Model: OR of local DCIS, adjusted for demographic and clinical factors | L, LR, LT, or LRT | Unknown vs. married | 91 months Total sample size: 1,103 | 0.61 (0.14; 2.64)
Marital status/local invasive carcinoma recurrence
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by followup time and age | LR or L | Formerly married vs. married | 62 months Total sample size: 709 | 1.4 (0.6; 3.2)
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by followup time and age | LR or L | Single vs. married | 62 months Total sample size: 709 | 1.4 (0.3; 5.9)
Warren, 2005^164^ Study design: OBS Model: OR of local invasive carcinoma, adjusted for demographic and clinical factors | L, LR, LT, or LRT | Unmarried vs. married | 91 months Total sample size: 1,103 | 2.07 (1.21; 3.56)
Warren, 2005^164^ Study design: OBS Model: OR of local invasive carcinoma, adjusted for demographic and clinical factors | L, LR, LT, or LRT | Unknown vs. married | 91 months Total sample size: 1,103 | 0.99 (0.22; 4.39)
Menarche age/local DCIS or invasive carcinoma recurrence
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | 13 vs. ≤12 | 62 months Total sample size: 709 | 1 (0.4; 1.6)
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | 14 vs. ≤12 | 62 months Total sample size: 709 | 0.8 (0.4; 1.8)
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | ≥ 15 vs. ≤12 | 62 months Total sample size: 709 | 0.8 (0.4; 1.8)
Menarche age/local invasive carcinoma recurrence
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by followup time and age | LR or L | 13 vs. ≤12 | 62 months Total sample size: 709 | 0.9 (0.4; 2)
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by followup time and age | LR or L | 14 vs. ≤12 | 62 months Total sample size: 709 | 0.6 (0.2; 2.2)
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by followup time and age | LR or L | ≥15 vs. ≤12 | 62 months Total sample size: 709 | 0.9 (0.3; 2.8)
Menopausal status/local DCIS or invasive carcinoma recurrence
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | Pre vs. post | 62 months Total sample size: 709 | 2.3 (1.1; 5)
Menopausal status/local invasive carcinoma recurrence
Hable, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by followup time and age | LR or L | Pre vs. post | 62 months Total sample size: 709 | 5.9 (1.8; 19.3)
Parity/local DCIS or invasive carcinoma recurrence
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | Nulliparous vs. parous | 62 months Total sample size: 709 | 1 (0.5; 1.8)
Parity/local invasive carcinoma recurrence
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by followup time and age | LR or L | Nulliparous vs. parous | 62 months Total sample size: 709 | 0.3 (0.1; 1.2)
Method of detection/local DCIS or invasive carcinoma recurrence
Bijker, 2006^282^ Study design: RCT Model: HR of local DCIS or invasive carcinoma recurrence adjusted by age, method of detection, histology, pathology, margin, and treatment | LR vs. L | Clinical symptoms vs. x-ray finding only | 126 months Total sample size: 1,010 | 1.55 (1.11; 2.16)
Fisher, 2001^284^ Study design: RCT Model: RR of local DCIS or invasive carcinoma recurrence in given covariate stratum, adjusted for treatment | LRT vs. LR | Clinical symptoms vs. x-ray finding only | 83 months Total sample size: 1,804 | 1.9 (1.36; 2.65)
Omlin, 2006^237^ Study design: OBS Model: HR of 10-year local DCIS or invasive recurrence, adjusted by age, method of detection, tumor size, necrosis, grade, margin, ER status, and treatment | LR or L | Symptom vs. x-ray only | 72 months Total sample size: 373 | 0.75 (0.37; 1.52)
Omlin, 2006^237^ Study design: OBS Model: HR of 10-year local DCIS or invasive recurrence, adjusted by age, method of detection, tumor size, necrosis, grade, margin, ER status, and treatment | LR or L | Unknown vs. x-ray only | 72 months Total sample size: 373 | 1.63 (0.54; 4.91)
Schouten van der Velden, 2007^163^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by age, method of detection, necrosis, treatment, size, and margin | M, MR, L, LR | Symptom vs. x-ray only | 59 months Total sample size: 798 | 2.1 (1.2; 3.7)
Meijnen, 2008^211^ Study design: OBS Model: HR of local DCIS or invasive carcinoma recurrence, adjusted by age, method of detection, treatment, margins, and grades | M, LR or L | Symptom vs. x-ray | 80.4 months Total sample size: 504 | 0.42 (0.13; 1.32)
Cutuli, 2001^160^ Study design: OBS Model: HR of local recurrence (not specific) adjusted by treatment, age, method of detection, margin, and family history | LR or L | Palpable vs. non palpable | 91 months Total sample size: 716 | 1.06 (0.7; 1.61)
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | Symptom vs. x-ray only | 62 months Total sample size: 709 | 1 (0.6; 1.6)
Method of detection/local invasive carcinoma recurrence
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by followup time and age | LR or L | Symptom vs. x-ray only | 62 months Total sample size: 709 | 0.7 (0.3; 1.5)
Kerlikowske, 2003^166^ Study design: OBS Model: OR of ipsilateral invasive carcinoma recurrence, adjusted by detection method, margin, nuclear grade, and type of calcification | L | Palpable vs. x-ray only | 77.9 months Total sample size: 1,036 | 4.9 (1.7; 14.2)
Oral contraceptives/local DCIS or invasive carcinoma recurrence
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | Ever vs. never | 62 months Total sample size: 709 | 0.6 (0.3; 1.3)
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | <5 years vs. never | 62 months Total sample size: 709 | 0.7 (0.3; 1.4)
Habel, 1998^238^ Study design: OBS Model: RR of local DCIS or invasive recurrence, adjusted by followup time and age | LR or L | ≥5 years vs. never | 62 months Total sample size: 709 | 0.6 (0.3; 1.4)
Oral contraceptives/local invasive carcinoma recurrence
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by followup time and age | LR or L | Ever vs. never | 62 months Total sample size: 709 | 0.6 (0.2; 1.4)
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by followup time and age | LR or L | <5 years vs. never | 62 months Total sample size: 709 | 0.6 (0.2; 1.8)
Habel, 1998^238^ Study design: OBS Model: RR of local invasive carcinoma recurrence, adjusted by followup time and age | LR or L | ≥5 years vs. never | 62 months Total sample size: 709 | 0.5 (0.2; 1.6)
Residual DCIS at re-excision/local DCIS or invasive carcinoma recurrence
Vargas, 2005^181^ Study design: OBS Model: HR of ipsilateral failure, adjusted by age, preradiation mammogram, mass in mammogram, boost energy, and residual DCIS at re-excision | LR or L | Yes vs. no | 84 months Total sample size: 410 | 2.54^*^
Lobular neoplasia/local DCIS or invasive recurrence
Rudloff, 2009^257^ Study design: OBS Model: HR of local DCIS or invasive recurrence, adjusted by age, method of detection, treatment, and lobular neoplasia | LR or L | Yes vs. no | 132 months Total sample size: 294 | 2.49 (1.33; 4.67)
Method of detection/local DCIS or invasive recurrence
Rudloff, 2009^257^ Study design: OBS Model: HR of local DCIS or invasive recurrence, adjusted by age, method of detection;, treatment, and lobular neoplasia | LR or L | Palpable mass vs. no | 132 months Total sample size: 294 | 2.05 (1.1; 3.81)
Period/contralateral DCIS
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of contralateral DCIS | M, LR, or L | 1994–1999 vs. 1988– 1993 | 55 months Total sample size: 23,547 | 1.68 (1.29; 2.17)
Period/contralateral invasive
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of contralateral invasive | M, LR, or L | 1994–1999 vs. 1988– 1993 | 55 months Total sample size: 23,547 | 0.95 (0.79; 1.15)
Period/local DCIS recurrence
Innos, 2008^259^ Study design: OBS Model: Poisson-regression derived incidence rate ratio of local DCIS recurrence | M, LR, or L | 1994–1999 vs. 1988– 1993 | 55 months Total sample size: 23,547 | 1.4 (0.99; 1.98)

Bold = significant

* Only means were reported

Table F35 Outcomes after mastectomy compared to lumpectomy in women with DCIS (observational studies)

Study | Events/Active vs. Events/Control | Subgroups, Outcomes | Estimate
Cutuli, 2001^160^ Country: France Length of followup, months: 91 Estimate: adjusted | 0/145 vs. 41/136 Proportion with the outcome in active: 0.003 (0;0.052) Proportion with outcomes in control: 0.301 (0.23;0.384) | Subgroup: overall treatment Outcome: local DCIS recurrence | 0.01 (0.00;0.13)
Cutuli, 2001^160^ Country: France Length of followup, months: 91 Estimate: adjusted | 3/145 vs. 17/136 Proportion with the outcome in active: 0.021 (0.007;0.062) Proportion with outcomes in control: 0.125 (0.079;0.192) | Subgroup: overall treatment Outcome: local invasive carcinoma recurrence | 0.15 (0.04;0.52)
Cutuli, 2001^160^ Country: France Length of followup, months: 91 Estimate: adjusted | 3/145 vs. 24/136 Proportion with the outcome in active: 0.021 (0.007;0.062) Proportion with outcomes in control: 0.176 (0.121;0.25) | Subgroup: overall treatment Outcome: local DCIS or invasive carcinoma recurrence | 0.10 (0.03;0.34)
Cutuli, 2001^160^ Country: France Length of followup, months: 91 Estimate: adjusted | 0/145 vs. 5/136 Proportion with the outcome in active: 0.003 (0;0.052) Proportion with outcomes in control: 0.037 (0.015;0.085) | Subgroup: overall treatment Outcome: nodal recurrence | 0.08 (0.00;1.50)
Cutuli, 2001^160^ Country: France Length of followup, months: 91 Estimate: adjusted | 2/145 vs. 6/136 Proportion with the outcome in active: 0.014 (0.003;0.053) Proportion with outcomes in control: 0.044 (0.02;0.095) | Subgroup: overall treatment Outcome: distant metastasis | 0.30 (0.06;1.53)
Cutuli, 2001^160^ Country: France Length of followup, months: 91 Estimate: adjusted | 8/133 vs. 9/123 Proportion with the outcome in active: 0.06 (0.03;0.116) Proportion with outcomes in control: 0.073 (0.039;0.135) | Subgroup: overall treatment Outcome: contralateral DCIS or invasive | 0.81 (0.30;2.17)
Schouten van der Velden, 2007^163^ Country: Netherlands Length of followup, months: 59 Estimate: adjusted | 11/408 vs. 61/237 Proportion with the outcome in active: 0.027 (0.015;0.048) Proportion with outcomes in control: 0.257 (0.206;0.317) | Subgroup: overall treatment Outcome: local DCIS or invasive carcinoma recurrence | 0.08 (0.04;0.16)
Schouten van der Velden, 2007^163^ Country: Netherlands Length of followup, months: 59 Estimate: adjusted | / vs./ Proportion with the outcome in active: (;) Proportion with outcomes in control: (;) | Subgroup: M vs L treatment Outcome: HR of local DCIS or invasive carcinoma recurrence, adjusted by age, method of detection, necrosis, treatment, size, and margin | 0.07 (0.03;0.16)
Werneke, 1995^182^ Country: United States Length of followup, months: 43 Estimate: crude | /29 vs. 3/11 Proportion with the outcome in active: 0.017 (0.001;0.217) Proportion with outcomes in control: 0.273 (0.09;0.586) | Subgroup: comedo necrosis Outcome: local DCIS or invasive carcinomarecurrence | NR (NR;NR)
Werneke, 1995^182^ Country: United States Length of followup, months: 43 Estimate: crude | 0/31 vs. 0/8 Proportion with the outcome in active: 0.016 (0.001;0.206) Proportion with outcomes in control: 0.056 (0.003;0.505) | Subgroup: noncomedo necrosis Outcome: local DCIS or invasive carcinomarecurrence | 0.04 (0.00;0.88)
Werneke, 1995^182^ Country: United States Length of followup, months: 43 Estimate: crude | 0/15 vs. 0/9 Proportion with the outcome in active: 0.067 (0.009;0.352) Proportion with outcomes in control: 0.05 (0.003;0.475) | Subgroup: unknown necrosis Outcome: loc al DCIS or invasive carcinomarecurrence | NR (NR;NR)
Werneke, 1995^182^ Country: United States Length of followup, months: 43 Estimate: crude | 0/33 vs. 2/15 Proportion with the outcome in active: 0.015 (0.001;0.196) Proportion with outcomes in control: 0.133 (0.034;0.405) | Subgroup: free margin Outcome: local DCIS or invasive carcinomarecurrence | NR (NR;NR)
Werneke, 1995^182^ Country: United States Length of followup, months: 43 Estimate: crude | 0/11 vs. 0/1 Proportion with the outcome in active: 0.042 (0.003;0.425) Proportion with outcomes in control: 0.25 (0.013;0.891) | Subgroup: involved margin Outcome: local DCIS or invasive carcinomarecurrence | 0.08 (0.00;1.79)
Werneke, 1995^182^ Country: United States Length of followup, months: 43 Estimate: crude | 0/31 vs. 1/12 Proportion with the outcome in active: 0.032 (0.005;0.196) Proportion with outcomes in control: 0.083 (0.012;0.413) | Subgroup: unknown margin Outcome: local DCIS or invasive carcinomarecurrence | NR (NR;NR)

Table F36 Outcomes after mastectomy compared to lumpectomy plus radiation in women with DCIS (observational studies)

Study | Events/Active vs. Events/Control | Subgroups, Outcomes | Estimate
Cutuli, 2001^160^ Country: France Length of followup, months: 91 Estimate: adjusted | 0/145 vs. 60/435 Proportion with the outcome in active: 0.003 (0;0.052) Proportion with outcomes in control: 0.138 (0.109;0.174) | Subgroup: overall treatment Outcome: local DCIS recurrence | 0.02 (0.00;0.35)
Cutuli, 2001^160^ Country: France Length of followup, months: 91 Estimate: adjusted | 3/145 vs. 24/435 Proportion with the outcome in active: 0.021 (0.007;0.062) Proportion with outcomes in control: 0.055 (0.037;0.081) | Subgroup: overall treatment Outcome: local invasive carcinoma recurrence | 0.36 (0.11;1.22)
Cutuli, 2001^160^ Country: France Length of followup, months: 91 Estimate: adjusted | 3/145 vs. 36/435 Proportion with the outcome in active: 0.021 (0.007;0.062) Proportion with outcomes in control: 0.083 (0.06;0.113) | Subgroup: overall treatment Outcome: local DCIS or invasive carcinoma recurrence | 0.23 (0.07;0.77)
Cutuli, 2001^160^ Country: France Length of followup, months: 91 Estimate: adjusted | 0/145 vs. 8/435 Proportion with the outcome in active: 0.003 (0;0.052) Proportion with outcomes in control: 0.018 (0.009;0.036) | Subgroup: overall treatment Outcome: nodal recurrence | 0.17 (0.01;3.01)
Cutuli, 2001^160^ Country: France Length of followup, months: 91 Estimate: adjusted | 2/145 vs. 6/435 Proportion with the outcome in active: 0.014 (0.003;0.053) Proportion with outcomes in control: 0.014 (0.006;0.03) | Subgroup: overall treatment Outcome: distant metastasis | 1.00 (0.20;5.01)
Cutuli, 2001^160^ Country: France Length of followup, months: 91 Estimate: adjusted | 8/133 vs. 30/420 Proportion with the outcome in active: 0.06 (0.03;0.116) Proportion with outcomes in control: 0.071 (0.05;0.1) | Subgroup: overall treatment Outcome: contralateral DCIS or invasive | 0.83 (0.37;1.86)
Schouten van der Velden, 2007^163^ Country: Netherlands Length of followup, months: 59 Estimate: adjusted | 11/408 vs. 11/153 Proportion with the outcome in active: 0.027 (0.015;0.048) Proportion with outcomes in control: 0.072 (0.04;0.125) | Subgroup: overall treatment Outcome: local DCIS or invasive carcinoma recurrence | 0.36 (0.15;0.84)
Schouten van der Velden, 2007^163^ Country: Netherlands Length of followup, months: 59 Estimate: adjusted | /vs./ Proportion with the outcome in active: (;) Proportion with outcomes in control: (;) | Subgroup: M vs LR treatment Outcome: HR of local DCIS or invasive carcinoma recurrence, adjusted by age, method of detection, necrosis, treatment, size, and margin | 0.23 (0.09;0.59)
Warneke, 1995^182^ Country: United States Length of followup, months: 43 Estimate: crude | 1/29 vs. 0/6 Proportion with the outcome in active: 0.017 (0.001;0.217) Proportion with outcomes in control: 0.071 (0.004;0.577) | Subgroup: comedo necrosis Outcome: local DCIS or invasive carcinoma recurrence | 1.97 (0.07;53.48)
Warneke, 1995^182^ Country: United States Length of followup, months: 43 Estimate: crude | 0/31 vs. 0/15 Proportion with the outcome in active: 0.016 (0.001;0.206) Proportion with outcomes in control: 0.031 (0.002;0.35) | Subgroup: noncomedo necrosis Outcome: local DCIS or invasive carcinoma recurrence | NR (NR;NR)
Warneke, 1995^182^ Country: United States Length of followup, months: 43 Estimate: crude | 1/33 vs. 0/9 Proportion with the outcome in active: 0.015 (0.001;0.196) Proportion with outcomes in control: 0.05 (0.003;0.475) | Subgroup: free margin Outcome: local DCIS or invasive carcinoma recurrence | 0.37 (0.02;6.38)
Warneke, 1995^182^ Country: United States Length of followup, months: 43 Estimate: crude | 0/11 vs. 0/1 Proportion with the outcome in active: 0.042 (0.003;0.425) Proportion with outcomes in control: 0.25 (0.013;0.891) | Subgroup: involved margin Outcome: local DCIS or invasive carcinoma recurrence | NR (NR;NR)
Warneke, 1995^182^ Country: United States Length of followup, months: 43 Estimate: crude | 0/31 vs. 0/11 Proportion with the outcome in active: 0.032 (0.005;0.196) Proportion with outcomes in control: 0.042 (0.003;0.425) | Subgroup: unknown margin Outcome: local DCIS or invasive carcinoma recurrence | NR (NR;NR)

Table F37 Outcomes after mastectomy from observational studies that did not report events and combined treatment options

Study | Treatments | Relative Measure of the Association
De Roos, 2005^261^ Country: Netherlands Length of followup, months: 43 Estimate: | Subgroup: treatment L vs. M Outcome: local DCIS or invasive recurrence, adjusted, stepwise manner, not specified | 7.84 (2.13;28.93)
De Roos, 2005^261^ Country: Netherlands Length of followup, months: 43 Estimate: | Subgroup: treatment LR vs. M Outcome: local DCIS or invasive recurrence, adjusted, stepwise manner, not specified | 2.43 (0.47;12.55)
Joslyn, 2006^161^ Country: USA Length of followup, months: NA Estimate: adjusted | Subgroup: BCS vs. M age >=51y and treatment Outcome: RR of mortality, adjusted by surgery, age, site, race, and radiation | 0.86 (0.76;0.98)
Joslyn, 2006^161^ Country: USA Length of followup, months: NA Estimate: adjusted | Subgroup: LR vs. L treatment Outcome: OR of breast cancer death, adjusted by age, size, and treatment | 1.40 (0.10;18.10)
Joslyn, 2006^161^ Country: USA Length of followup, months: NA Estimate: adjusted | Subgroup: M vs. L treatment Outcome: OR of breast cancer death, adjusted by age, size, and treatment | 1.80 (0.40;7.60)
Joslyn, 2006^161^ Country: USA Length of followup, months: NA Estimate: adjusted | Subgroup: LR vs. L treatment Outcome: OR of ipsilateral invasive recurrence, adjusted by age, size, and treatment | 0.10 (0.00;1.00)
Joslyn, 2006^161^ Country: USA Length of followup, months: NA Estimate: adjusted | Subgroup: M vs. L treatment Outcome: OR of ipsilateral invasive recurrence, adjusted by age, size, and treatment | 0.10 (0.00;0.50)
Joslyn, 2006^161^ Country: USA Length of followup, months: NA Estimate: adjusted | Subgroup: LR vs. L treatment Outcome: OR of contralateral invasive recurrence, adjusted by age, size, and treatment | 3.60 (0.30;43.50)
Joslyn, 2006^161^ Country: USA Length of followup, months: NA Estimate: adjusted | Subgroup: M vs. L treatment Outcome: OR of contralateral invasive recurrence, adjusted by age, size, and treatment | 0.70 (0.20;2.90)

Table F38 Observational studies of control and systemic outcomes stratified by mastectomy

Author | Probability or Rate | Length of Followup | Number Active
M/all cause mortality
Di Saverio S, 2008^212^ | 0.013 | 120
Tunon-de-Lara C, 2001^155^ | 0.00028 | 120 | 208
Lee LA, 2006^210^ | 0.1 | 144 | 430
Meijnen P, 2008^211^ | 0.006 | 96 | 294
Ellsworth RE, 2007^239^ | 0.017 (0.001, 0.217) | NA | 29
M/breast cancer mortality
Lee LA, 2006^210^ | 0.008 | 144 | 430
Meijnen P, 2008^211^ | 0.006 | 96 | 294
Tunon-de-Lara C, 2001^155^ | 0.014 (0.005, 0.044) | 86 | 208
Dimpfl T, 1996^218^ | 0.006 (0, 0.093) | 78.4 | 78
M/distant metastasis
Lee LA, 2006^210^ | 0.008 | 144 | 430
Bonnier P, 1999^154^ | 0.01 (0, 0.02) | 84 | 21
Meijnen P, 2008^211^ | 0.009 | 96 | 294
Tunon-de-Lara C, 2001^155^ | 0.005 (0.001, 0.033) | 86 | 208
Cutuli B, 2001^160^ | 0.014 (0.003, 0.053) | 91 | 145
Asjoe FT, 2007^207^ | 0.031 (0.004, 0.191) | 36 | 32
Dimpfl T, 1996^218^ | 0.006 (0, 0.093) | 78.4 | 78
M/contralateral DCIS or invasive carcinoma
Meijnen P, 2008^211^ | 0.065 | 96 | 294
Cutuli B, 2001^160^ | 0.06 (0.03, 0.116) | 91 | 133
M/contralateral invasive carcinoma
Miller NA, 2001^203^ | 0.026 (0.002, 0.31) | 80.4 | 18
M/local DCIS or invasive carcinoma recurrence
Tunon-de-Lara C, 2001^155^ | 0.0003 | 120 | 208
Schouten van der Velden AP, 2006^250^ | 0.067 | 48 | 173
Ringberg A, 2000^186^ | 0.04 | 60 | 119
Schouten van der Velden AP, 2007, 17544591 | 0.013 | 60 | 408
Lee LA, 2006^210^ | 0.01 | 144 | 430
Meijnen P, 2008^211^ | 0.009 | 96 | 294
Cutuli B, 2001^160^ | 0.021 (0.007, 0.062) | 91 | 145
Asjoe FT, 2007^207^ | 0.062 (0.016, 0.218) | 36 | 32
Cataliotti L, 1992^213^ | 0.029 (0.009, 0.086) | 94 | 103
Ciatto S, 1990^214^ | 0.014 (0.005, 0.043) | 66 | 210
Dimpfl T, 1996^218^ | 0.013 (0.002, 0.085) | 78.4 | 78
Stallard S, 2001^223^ | 0.007 (0, 0.107) | 132 | 67
Jha MK, 2001^242^ | 0.003 (0, 0.045) | 88 | 168
Warneke J, 1995^182^ | 0.013 (0.002, 0.089) | 47 | 75
Bonnier P, 1999^154^ | 0.019 (0.007, 0.049) | 51 | 214
M/local invasive carcinoma recurrence
Lee LA, 2006^210^ | 0.005 | 144 | 430
Kricker a, 2004^246^ | 0 | 36 | 327
Meijnen P, 2008^211^ | 0.004 | 96 | 294
Tunon-de-Lara C, 2001^155^ | 0.024 (0.01, 0.056) | 86 | 208
Cutuli B, 2001^160^ | 0.021 (0.007, 0.062) | 91 | 145
Miller NA, 2001^203^ | 0.056 (0.008, 0.307) | 80.4 | 18
Ciatto S, 1990^214^ | 0.01 (0.002, 0.037) | 66 | 210
Ellsworth RE, 200^239^ | 0.017 (0.001, 0.217) | NA | 29
Warnberg F, 1999^228^ | 0.011 (0.001, 0.149) | 58 | 46
M/local DCIS recurrence
Meijnen P, 2008^211^ | 0.005 | 96 | 294
Tunon-de-Lara C, 2001^155^ | 0.005 (0.001, 0.033) | 86 | 208
Cutuli B, 2001^160^ | 0.003 (0, 0.052) | 91 | 145
Fish EB, 1998^183^ | 0.026 (0.002, 0.31) | 60 | 18
Miller NA, 2001^203^ | 0.026 (0.002, 0.31) | 80.4 | 18
Ciatto S, 1990^214^ | 0.005 (0.001, 0.033) | 66 | 210
Warnberg F, 1999^228^ | 0.022 (0.003, 0.139) | 58 | 46
M/regional LN recurrence
Tunon-de-Lara C, 2001^155^ | 0.01 (0.002, 0.038) | 86 | 208
Fish EB, 1998^183^ | 0.056 (0.008, 0.307) | 60 | 18
Cutuli B, 2001^160^ | 0.003 (0, 0.052) | 91 | 145
Stallard S, 2001^223^ | 0.03 (0.007, 0.112) | 132 | 67
Asjoe FT, 2007^207^ | 0.031 (0.004, 0.191) | 36 | 32
M/local DCIS or invasive carcinoma recurrence per 100 patient-years at risk
Ciatto S, 1990^214^ | 0.002 | 66 | 210

Table F39 Observational studies of control and systemic outcomes and treatment based on multivariate analysis

Author | Probability or Rate | Length of Followup | Number Active
M vs. LR
Meijnen P, 2008^211^ HR of local DCIS or invasive carcinoma recurrence, adjusted by age, method of detection, treatment, margins, and grades | 0.13 (0.03, 0.57) | 80.4 | 504
Schouten van der Velden AP, 2007^163^ HR of local DCIS or invasive carcinoma recurrence, adjusted by age, method of detection, necrosis, treatment, size, and margin | 0.23 (0.09, 0.59) | 59 | 798
M vs. L
Meijnen P, 2008^211^ HR of local DCIS or invasive carcinoma recurrence, adjusted by age, method of detection, treatment, margins, and grades | 0.037 (0.008, 0.182) | 80.4 | 504
Schouten van der Velden AP, 2007^163^ HR of local DCIS or invasive carcinoma recurrence, adjusted by age, method of detection, necrosis, treatment, size, and margin | 0.07 (0.03, 0.16) | 59 | 798
Warnberg F, 2001^226^ OR of ipsilateral invasive recurrence, adjusted by age, size, and treatment | 0.1 (0, 0.5) | NA | NA
Warnberg F, 2001^226^ OR of contralateral invasive recurrence, adjusted by age, size, and treatment | 0.7 (0.2, 2.9) | NA | NA
Warnberg F, 2001^226^ OR of breast cancer death, adjusted by age, size, and treatment | 1.8 (0.4, 7.6) | NA | NA
L vs. LR or M
Smith GL, 2006^165^ HR of local DCIS or invasive carcinoma recurrence, adjusted by age, race, year of diagnosis, site, prognostic score, and treatment. | 4.02 (2.83, 5.69) | 28.8 | 14202
M vs. L or LR
Li CI, 2006^249^ HR of local or contralateral invasive carcinoma, adjusted by age, registry, race, and LN removal | 0.4 (0.3, 0.5) | NA | 37692
Li CI, 2006^249^ HR of contralateral invasive carcinoma, adjusted by age, registry, race, and LN removal | 1.2 (0.9, 1.7) | NA | 37692
Joslyn SA, 2006^161^ RR of mortality, adjusted by surgery, age, site, race, and radiation | 0.96 (0.85, 1.09) | NA | 41245
No vs. LR
Innos K, 2008^259^ Poisson-regression derived incidence rate ratio of local DCIS recurrence | 5 (2.05, 12.21) | 55 | 23547
Innos K, 2008^259^ Poisson-regression derived incidence rate ratio of local invasive recurrence | 22.68 (11.8, 43.59) | 55 | 23547
Li CI, 2006^249^ HR of local invasive carcinoma recurrence, adjusted by age, registry, race, and LN removal | 1.7 (0.6, 4.3) | NA | 37692
Li CI, 2006^249^ HR of contralateral invasive carcinoma, adjusted by age, registry, race, and LN removal | 1.1 (0.5, 2.4) | NA | 37692
Li CI, 2006^249^ HR of local or contralateral invasive carcinoma, adjusted by age, registry, race, and LN removal | 1.5 (1, 1.7) | NA | 37692
LR vs. L
Cutuli B, 2001^160^ HR of local recurrence (not specific) adjusted by treatment, age, method of detection, margin, and family history | 0.444 (0.298, 0.662) | 91 | 716
Warnberg F, 2001^226^ OR of ipsilateral invasive recurrence, adjusted by age, size, and treatment | 0.1 (0, 1) | NA | NA
Warnberg F, 2001^226^ OR of contralateral invasive recurrence, adjusted by age, size, and treatment | 3.6 (0.3, 43.5) | NA | NA
Warnberg F, 2001^226^ OR of breast cancer death, adjusted by age, size, and treatment | 1.4 (0.1, 18.1) | NA | NA
Innos K, 2008^259^ Poisson-regression derived incidence rate ratio of local DCIS recurrence | 0.37 (0.24, 0.57) | 55 | 23547
Innos K, 2008^259^ Poisson-regression derived incidence rate ratio of local invasive recurrence | 0.33 (0.20, 0.52) | 55 | 23547
Li CI, 2006^249^ HR of local invasive carcinoma recurrence, adjusted by age, registry, race, and LN removal | 0.7 (0.5, 1.2) | NA | 37692
Li CI, 2006^249^ HR of contralateral invasive carcinoma, adjusted by age, registry, race, and LN removal | 1 (0.9, 1.3) | NA | 37692
Li CI, 2006^249^ HR of local or contralateral invasive carcinoma, adjusted by age, registry, race, and LN removal | 0.6 (0.6, 0.7) | NA | 37692
Vargas C, 2005^181^ HR of ipsilateral failure, adjusted by age, whole breast radiation, and margin | 0.18 | 84 | 410
Smith BD, 2006^151^ HR of local DCIS recurrence adjusted by age, race, cormobidity, tumor size, histology, grade, treatment, martial status, median income, urban-rural status | 0.23 (0.12, 0.45) | 60 | 3409
Smith BD, 2006^151^ HR of local invasive carcinoma recurrence adjusted by age, race, cormobidity, tumor size, histology, grade, treatment, martial status, median income, urban-rural status | 0.27 (0.16, 0.45) | 60 | 3409
Stallard S, 2001^223^ HR of any DCIS or invasive carcinoma recurrence, adjusted by distance from nipple to lesion, grade, and radiation | 0.43 (0.1, 1.92) | 132 | 220
Smith BD, 2006^151^ HR of any second breast cancer event (local DCIS, local invasive carcinoma, and/or subsequent mastectomy) adjusted by age, race, cormobidity, tumor size, histology, grade, treatment, martial status, median income, urban-rural status | 0.32 (0.24, 0.44) | 60 | 3409
Habel LA, 1998^238^ RR of local DCIS or invasive recurrence, adjusted by follow-up time and age | 0.5 (0.3, 0.7) | 709 | 62
Habel LA, 1998^238^ RR of local invasive carcinoma recurrence, adjusted by follow-up time and age | 0.4 (0.2, 0.6) | 709 | 62
Rakovitch E, 2008^243^ HR of local DCIS or invasive recurrence, adjusted by radiation, nuclear grade, multifocality, and margin | 0.46 (0.29, 0.74) | 615 | NA
Rakovitch E, 2008^243^ HR of local DCIS or invasive recurrence, adjusted by radiation, nuclear grade, multifocality, and margin, in negative margin cases | 0.5 (0.3, 0.83) | 615 | NA
Warren JL, 2005^164^ HR of local DCIS or invasive carcinoma, adjusted for demographic and clinical factors | 0.64 (0.44, 0.92) | 1103 | 91
Warren JL, 2005^164^ OR of local invasive carcinoma, adjusted for demographic and clinical factors | 0.4 (0.22, 0.74) | 1103 | 91
Warren JL, 2005^164^ OR of local DCIS, adjusted for demographic and clinical factors | 0.9 (0.55, 1.45) | 1103 | 91
Cutuli B, 2002^188^ RR of local DCIS or invasive carcinoma recurrence, adjusted by radiation, age, tumor stage, margin, and family history | 0.35 (0.25, 0.51) | 705 | 84
Chuwa EW, 2008^200^ Local DCIS or invasive carcinoma recurrence, adjusted by age, menopausal status, symptom, grade, size, hormone receptor status, necrosis, margin, radiation, tamoxifen | 0.90 (0.22, 3.70) | 170 | 86
MacDonald HR, 2006^192^ RR for time to local DCIS or invasive carcinoma recurrence | 0.17 (0.02, 1.31) | 272 | 53
MacDonald HR, 2006^192^ RR for time to invasive carcinoma recurrence | 0.67 (0.07, 6.52) | 272 | 53
MacDonald HR, 2006^192^ RR for time to local DCIS or invasive carcinoma recurrence, adjusted by age | 0.17 (0.02, 1.31) | 272 | 53
MacDonald HR, 2006^192^ RR for time to invasive carcinoma recurrence, adjusted by age | 0.68 (0.07, 6.6) | 272 | 53
MacDonald HR, 2006^192^ RR for time to local DCIS or invasive carcinoma recurrence, adjusted by size | 0.14 (0.02, 1.11) | 272 | 53
MacDonald HR, 2006^192^ RR for time to invasive carcinoma recurrence, adjusted by size | 0.63 (0.07, 6.13) | 272 | 53
MacDonald HR, 2006^192^ RR for time to local DCIS or invasive carcinoma recurrence, adjusted by grade | 0.17 (0.02, 1.31) | 272 | 53
MacDonald HR, 2006^192^ RR for time to invasive carcinoma recurrence, adjusted by grade | 0.68 (0.07, 6.56) | 272 | 53
MacDonald HR, 2006^192^ RR for time to local DCIS or invasive carcinoma recurrence, adjusted by necrosis | 0.17 (0.02, 1.28) | 272 | 53
MacDonald HR, 2006^192^ RR for time to invasive carcinoma recurrence, adjusted by necrosis | 0.7 (0.07, 6.81) | 272 | 53
Joslyn SA, 2006^161^ RR of mortality, adjusted by surgery, age, site, race, and radiation | 0.63 (0.53, 0.75) | 41245 | NA
Rudloff U, 2009^257^ HR of local DCIS or invasive recurrence, adjusted by age, method of detection, treatment, and lobular neoplasia | 0.33 (0.17, 0.67) | 132 | 294
Radiation with boost vs. without boost
Omlin A, 2006^237^ HR of 10-year local DCIS or invasive recurrence, adjusted by age, method of detection, tumor size, necrosis, grade, margin, ER status, and treatment | 0.45 (0.23, 0.9) | 373 | 72
Radiation without boost vs. no radiation
Omlin A, 2006^237^ HR of 10-year local DCIS or invasive recurrence, adjusted by age, method of detection, tumor size, necrosis, grade, margin, ER status, and treatment | 0.33 (0.16, 0.71) | 373 | 72
Radiation with boost vs. no radiation
Omlin A, 2006^237^ HR of 10-year local DCIS or invasive recurrence, adjusted by age, method of detection, tumor size, necrosis, grade, margin, ER status, and treatment | 0.15 (0.06, 0.36) | 373 | 72
Tamoxifen vs. no tamoxifen
Warren JL, 2005^164^ HR of local DCIS or invasive carcinoma, adjusted for demographic and clinical factors | 1.18 (0.74, 1.88) | 1103 | 91
Warren JL, 2005^164^ OR of local invasive carcinoma, adjusted for demographic and clinical factors | 1.19 (0.55, 2.54) | 1103 | 91
Warren JL, 2005^164^ OR of local DCIS, adjusted for demographic and clinical factors | 1.2 (0.64, 2.27) | 1103 | 91
Boost energy 9mev vs. 10 mEV
Vargas C, 2005^181^ HR of ipsilateral failure, adjusted by age, preradiation mammogram, mass in mammogram, boost energy, and residual DCIS at re-excision | 1.4 | 410 | 84
Vargas C, 2005^181^ HR of ipsilateral failure, adjusted by age, preradiation mammogram, mass in mammogram, boost energy, and margin | 1.41 | 410 | 84
Boost energy photons vs. electrons
Ben-David MA, 2007^206^ OR of grade 2 maximal acute toxicity, adjusted, not specified | 5.1 (1.4, 19.1) | 198 | 74.4
RT alone vs. LR
Innos K, 2008^259^ Poisson-regression derived incidence rate ratio of local DCIS recurrence | 3.15 (0.42, 23.23) | 55 | 23547

Table F40 Observational studies of control and systemic outcomes stratified by lumpectomy alone

Author | Probability or Rate | Length of Followup | Number Active
L/breast cancer mortality
Kestin LL, 2000^208^ | 0 | 120 | 31
Lee LA, 2006^210^ | 0.004 | 144 | 496
Vargas C, 2005^181^ | 0.063 | 96 | 54
Meijnen P, 2008^211^ | 0.032 | 96 | 91
Kerlikowske K, 2003^166^ | 0.01 (0.005, 0.018) | 77.9 | 1036
Dimpfl T, 1996^218^ | 0.011 (0.001, 0.149) | 78.4 | 46
Szelei-Stevens KA, 2000^224^ | 0.047 (0.012, 0.168) | 104.4 | 43
Gilleard O, 2008^236^ | 0.009 (0.002, 0.036) | 53 | 215
L/all cause mortality
Kestin LL, 2000^208^ | 0.416 | 120 | 31
Lee LA, 2006^210^ | 0.11 | 144 | 496
Vargas C, 2005^181^ | 0.255 | 96 | 54
Meijnen P, 2008^211^ | 0.043 | 96 | 91
L/distant metastasis
Lee LA, 2006^210^ | 0.004 | 144 | 496
Vargas C, 2005^181^ | 0.063 | 96 | 54
Meijnen P, 2008^211^ | 0.043 | 96 | 91
Kerlikowske K, 2003^166^ | 0.007 (0.003, 0.014) | 77.9 | 1036
Dimpfl T, 1996^218^ | 0.011 (0.001, 0.149) | 78.4 | 46
Szelei-Stevens KA, 2000^224^ | 0.047 (0.012, 0.168) | 104.4 | 43
Douglas-Jones AG, 2002^235^ | 0.009 (0.001, 0.059) | NA | 115
L/local DCIS or invasive carcinoma recurrence
Rakovitch E, 2007^243^ | 0.28 | 120 | 310
Kestin LL, 2000^208^ | 0.078 | 120 | 31
Adepoju LJ, 2006^204^ | 0.295 | 120 | 92
Omlin A, 2006^237^ | 0.54 (0.33, 0.76) | 120 | 57
Cutuli B, 2002^188^ | 0.438 (0.3, 0.577) | 120 | 190
Lee LA, 2006^210^ | 0.31 | 144 | 496
Schouten van der Velden AP, 2006^250^ | 0.169 | 48 | 329
Ringberg A, 2000^186^ | 0.21 | 60 | 121
Wong JS, 2006^153^ | 0.0012 | 60 | 158
Takeda A, 2001^205^ | 0.189 | 60 | 66
Vargas C, 2005^181^ | 0.419 | 96 | 54
Meijnen P, 2008^211^ | 0.156 | 96 | 91
Gilleard O, 2008^236^ | 0.17 | 96 | 215
Chan KC, 2001^159^ | 0.186 (0.128, 0.263) | 47 | 129
Cataliotti L, 1992^213^ | 0.109 (0.046, 0.236) | 94 | 46
Ciatto S, 1990^214^ | 0.054 (0.014, 0.192) | 66 | 37
Dimpfl T, 1996^218^ | 0.13 (0.06, 0.261) | 78.4 | 46
Szelei-Stevens KA, 2000, 224 | 0.14 (0.064, 0.278) | 104.4 | 43
Douglas-Jones AG, 2002^235^ | 0.122 (0.073, 0.195) | NA | 115
Ottesen GL, 2000^240^ | 0.321 (0.255, 0.396) | 120 | 168
Liberman L, 1997^184^ | 0.227 (0.154, 0.321) | 75 | 97
Warneke J, 1995^182^ | 0.107 (0.035, 0.284) | 39 | 28
Holland PA, 1998^229^ | 0.103 (0.05, 0.201) | 35 | 68
Idvall I, 2003^232^ | 0.256 (0.186, 0.341) | NA | 121
Bonnier P, 1999^154^ | 0.119 (0.05, 0.256) | 51 | 42
Rudloff U, 2009, 257 | 0.279 | 120 | 200
West JG, 2007^260^ | 0.061 (0.026, 0.138) | 86 | 82
L/true DCIS or invasive carcinoma recurrence
Kestin LL, 2000^208^ | 0.078 | 120 | 31
Ottesen GL, 2000^240^ | 0.304 (0.239, 0.377) | 120 | 168
L/local DCIS recurrence
Meijnen P, 2008^211^ | 0.079 | 96 | 91
Kerlikowske K, 2003^166^ | 0.108 (0.091, 0.129) | 77.9 | 1036
Chan KC, 2001^159^ | 0.14 (0.09, 0.211) | 47 | 129
Fish EB, 1998^183^ | 0.193 (0.124, 0.289) | 60 | 88
Miller NA, 2001^203^ | 0.193 (0.124, 0.289) | 60 | 88
Kestin LL, 2000^208^ | 0.032 (0.005, 0.196) | 84 | 31
Lee LA, 2006^210^ | 0.115 (0.09, 0.146) | 72 | 496
Ciatto S, 1990^214^ | 0.013 (0.001, 0.178) | 66 | 37
Szelei-Stevens KA, 2000^224^ | 0.047 (0.012, 0.168) | 104.4 | 43
Douglas-Jones AG, 2002^235^ | 0.052 (0.024, 0.111) | NA | 115
Gilleard O, 2008^236^ | 0.037 (0.019, 0.073) | 53 | 215
Ottesen GL, 2000^240^ | 0.173 (0.123, 0.237) | 120 | 168
Rakovitch E, 2007^243^ | 0.1 (0.071, 0.139) | 82.8 | 310
L/true DCIS recurrence
Ottesen GL, 2000^240^ | 0.155 (0.108, 0.218) | 120 | 168
L/local invasive carcinoma recurrence
Rakovitch E, 2007^243^ | 0.15 | 120 | 310
Kerlikowske K, 2003^166^ | 0.082 (0.066, 0.098) | 60 | 1036
Lee LA, 2006^210^ | 0.12 | 144 | 496
Meijnen P, 2008^211^ | 0.084 | 96 | 91
Gilleard O, 2008^236^ | 0.13 | 96 | 215
Chan KC, 2001^159^ | 0.047 (0.021, 0.1) | 47 | 129
Fish EB, 1998^183^ | 0.068 (0.031, 0.144) | 60 | 88
Miller NA, 2001^203^ | 0.068 (0.031, 0.144) | 60 | 88
Kestin LL, 2000^208^ | 0.032 (0.005, 0.196) | 84 | 31
Ciatto S, 1990^214^ | 0.054 (0.014, 0.192) | 66 | 37
Szelei-Stevens KA, 2000^224^ | 0.093 (0.035, 0.223) | 104.4 | 43
Douglas-Jones AG, 2002^235^ | 0.07 (0.035, 0.133) | NA | 115
Ottesen GL, 2000^240^ | 0.149 (0.103, 0.211) | 120 | 168
L/true invasive carcinoma recurrence
Ottesen GL, 2000^240^ | 0.149 (0.103, 0.211) | 120 | 168
L/local DCIS or invasive carcinoma recurrence per 100 patient-years at risk
Ciatto S, 1990^214^ | 0.011 | 66 | 37
MacAusland SG, 2007^215^ | 0.086 (0.055, 0.13) | 55.2 | 222
West JG, 2007^260^ | 0.78 | 86 | 82
L/regional invasive carcinoma recurrence
Kerlikowske K, 2003^166^ | 0.018 (0.012, 0.029) | 77.9 | 1036
L/contralateral DCIS or invasive carcinoma
Kestin LL, 2000^208^ | 0.036 | 120 | 31
Adepoju LJ, 2006^204^ | 0.026 | 120 | 92
Meijnen P, 2008^211^ | 0.045 | 96 | 91
Cutuli B, 2002^188^ | 0.075 | 84
Ottesen GL, 2000^240^ | 0.024 (0.009, 0.062) | 120 | 168
L/contralateral DCIS
Ottesen GL, 2000^240^ | 0.012 (0.003, 0.046) | 120 | 168
L/contralateral invasive carcinoma
Fish EB, 1998^183^ | 0.057 (0.024, 0.129) | 60 | 88
Miller NA, 2001^203^ | 0.057 (0.024, 0.129) | 60 | 88
Ottesen GL, 2000^240^ | 0.012 (0.003, 0.046) | 120 | 168

Table F41 Observational studies of control and systemic outcomes stratified by lumpectomy + radiation therapy

Author | Probability or Rate | Length of Followup | Number Active
LR/breast cancer mortality
Vapiwala N, 2006^219^ | 0.04 (0.01, 0.16) | 180 | 192
Solin LJ, 1996^221^ | 0.04 (0.01, 0.07) | 180 | 270
Jhingran A, 2002^251^ | 0 | 120 | 150
Rodrigues N, 2002^167^ | 0.03 | 120 | 280
Vicini FA, 2000^174^ | 0.009 | 120 | 148
Vargas C, 2005^181^ | 0.012 | 120 | 313
Harris ELR, 2000^172^ | 0.03 | 120 | 146
Fowble B, 1997^230^ | 0 | 120 | 110
Amichetti M, 1997^199^ | 0 | 120 | 139
Lee LA, 2006^210^ | 0.02 | 144 | 310
Chuwa EW, 2008^200^ | 0 | 60 | 60
Meijnen P, 2008^211^ | 0.02 | 96 | 119
Mirza NQ, 2000^201^ | 0.018 (0.005, 0.07) | 132 in DCIS, 144 in DCIS with microinvasion | 109
Dimpfl T, 1996^218^ | 0.013 (0.001, 0.178) | 78.4 | 37
LR/all cause mortality
Vapiwala N, 2006^219^ | 0.29 (0.18, 0.44) | 180 | 192
Solin LJ, 1996^221^ | 0.13 (0.07, 0.19) | 180 | 270
Jhingran A, 2002^251^ | 0.06 | 120 | 150
Vicini FA, 2001^180^ | 0.046 | 120 | 148
Vargas C, 2005^181^ | 0.088 | 120 | 313
Fowble B, 1997^230^ | 0.06 | 120 | 110
Rodrigues N, 2002^167^ | 0.12 | 120 | 280
Harris ELR, 2000^172^ | 0.06 | 120 | 146
Amichetti M, 1997^199^ | 0.07 | 120 | 139
Lee LA, 2006^210^ | 0.11 | 144 | 310
Meijnen P, 2008^211^ | 0.031 | 96 | 119
LR/distant metastasis
Vargas C, 2005^181^ | 0.012 | 120 | 313
Lee LA, 2006^210^ | 0.02 | 144 | 310
Meijnen P, 2008^211^ | 0.042 | 96 | 119
Solin LJ, 1996^221^ | 0.04 (0.01, 0.06) | 180 | 270
Bonnier P, 1999^154^ | 0.03 (0.02, 0.04) | 60 | 120
Cutuli B, 2002^188^ | 0.014 (0.006, 0.028) | 84 | 515
Amichetti M, 1997^199^ | 0.004 (0, 0.054) | 81 | 139
Mirza NQ, 2000^201^ | 0.018 (0.005, 0.07) | 132 in DCIS, 144 in DCIS with microinvasion | 109
Dimpfl T, 1996^218^ | 0.013 (0.001, 0.178) | 78.4 | 37
Vapiwala N, 2006^219^ | 0.01 (0.003, 0.041) | 74.4 | 192
Fowble B, 1997^230^ | 0.009 (0.001, 0.062) | 63.6 | 110
Rodrigues N, 2004^233^ | 0.005 (0, 0.073) | 34 | 101
Jhingran A, 2002^251^ | 0.003 (0, 0.051) | 63 | 150
LR/non-brest second malignancy
Vapiwala N, 2006^219^ | 0.3 (0.17, 0.49) | 180 | 192
Amichetti M, 1997^199^ | 0.029 (0.011, 0.074) | 81 | 139
LR/secondary malignancy
Amichetti M, 1999^217^ | 0.009 (0.001, 0.061) | 68 | 112
Vapiwala N, 2006^219^ | 0.068 (0.04, 0.113) | 74.4 | 192
LR/mesothelioma
Deutsch M, 2007^189^ | 0.002 (0, 0.017) | NA | 410
LR/local DCIS or invasive carcinoma recurrence
Vapiwala N, 2006^219^ | 0.15 (0.08, 0.26) | 180 | 192
Solin LJ, 1996^221^ | 0.19 (0.13, 0.25) | 180 | 270
Omlin A, 2006^237^ | 0.28 (0.17, 0.39) | 120 | 166
Cutuli B, 2002^188^ | 0.182 (0.133, 0.23) | 120 | 515
Rakovitch E, 2008^243^ | 0.18 | 120 | 305
Vicini FA, 2000^174^ | 0.124 | 120 | 148
Vargas C, 2005^181^ | 0.094 | 120 | 313
Harris ELR, 2000^172^ | 0.12 | 120 | 146
Adepoju LJ, 2006^204^ | 0.084 | 120 | 211
Fowble B, 1997^230^ | 0.15 | 120 | 110
Rodrigues N, 2002^167^ | 0.13 | 120 | 280
Amichetti M, 1997^199^ | 0.14 | 120 | 139
Lee LA, 2006^210^ | 0.24 | 144 | 310
Ringberg A, 2000^186^ | 0.06 | 60 | 66
Schouten van der Velden AP, 2007^163^ | 0.094 | 60 | 153
Takeda A, 2001^205^ | 0.06 | 60 | 48
Neuschatz AC, 2001^158^ | 0.138 | 60 | 55
Chuwa EW, 2008^200^ | 0.058 | 60 | 60
Meijnen P, 2008^211^ | 0.088 | 96 | 119
Chan KC, 2001^159^ | 0.111 (0.028, 0.352) | 47 | 18
Mirza NQ, 2000^201^ | 0.147 (0.092, 0.226) | 132 in DCIS, 144 in DCIS with microinvasion | 109
Cataliotti L, 1992^213^ | 0.088 (0.029, 0.24) | 94 | 34
Ciatto S, 1990^214^ | 0.058 (0.026, 0.124) | 66 | 103
SahooS, 2005^216^ | 0.126 (0.075, 0.205) | 63 | 103
Dimpfl T, 1996^218^ | 0.054 (0.014, 0.192) | 78.4 | 37
Pinsky RW, 2007^244^ | 0.082 (0.061, 0.109) | NA | 513
Liberman L, 1997^184^ | 0.169 (0.096, 0.28) | 75 | 65
Warneke J, 1995^182^ | 0.023 (0.001, 0.277) | 37 | 21
Bonnier P, 1999^154^ | 0.091 (0.064, 0.128) | 51 | 319
Jhingran A, 2002^251^ | 0.12 | 120 | 150
Rudloff U, 2009^257^ | 0.119 | 120 | 91
West JG, 2007^260^ | 0.014 (0.002, 0.093) | 99 | 71
LR/true DCIS or invasive carcinoma recurrence
Jhingran A, 2002^251^ | 0.11 | 120 | 150
Vicini FA, 2001^180^ | 0.098 | 120 | 148
Amichetti M, 1999^217^ | 0.062 (0.03, 0.125) | 68 | 112
LR/true DCIS recurrence
Vicini FA, 2001^180^ | 0.029 | 120 | 148
LR/true invasive carcinoma recurrence
Vicini FA, 2001^180^ | 0.067 | 120 | 148
LR/local DCIS recurrence
Jhingran A, 2002^251^ | 0.03 | 120 | 150
Meijnen P, 2008^211^ | 0.014 | 96 | 119
Vicini FA, 2001^180^ | 0.027 (0.01, 0.07) | 86.4 | 148
Rodrigues N, 2002^167^ | 0.043 (0.024, 0.074) | 98.4 | 280
Harris ELR, 2000^172^ | 0.034 (0.014, 0.08) | 85.2 | 146
Chan KC, 2001^159^ | 0.111 (0.028, 0.352) | 47 | 18
Fish EB, 1998^183^ | 0.111 (0.028, 0.352) | 60 | 18
Cutuli B, 2002^188^ | 0.05 (0.035, 0.073) | 84 | 515
Amichetti M, 1997^199^ | 0.05 (0.024, 0.102) | 81 | 139
Miller NA, 2001^203^ | 0.111 (0.028, 0.352) | 60 | 18
Lee LA, 2006^210^ | 0.09 (0.063, 0.128) | 72 | 310
Ciatto S, 1990^214^ | 0.01 (0.001, 0.066) | 66 | 103
SahooS, 2005^216^ | 0.087 (0.046, 0.159) | 63 | 103
Solin LJ, 1996^221^ | 0.078 (0.051, 0.116) | 123.6 | 270
Fowble B, 1997^230^ | 0.005 (0, 0.068) | 63.6 | 110
Rodrigues N, 2004^233^ | 0.01 (0.001, 0.067) | 34 | 101
Rakovitch E, 2008^243^ | 0.062 (0.04, 0.096) | 58.8 | 305
LR/local invasive carcinoma recurrence
Lee LA, 2006^210^ | 0.12 | 144 | 310
Rakovitch E, 2008^243^ | 0.08 | 120 | 305
Jhingran A, 2002^251^ | 0.03 | 120 | 150
Vicini FA, 2001^180^ | 0.088 (0.052, 0.145) | 86.4 | 148
Meijnen P, 2008^211^ | 0.075 | 96 | 119
Rodrigues N, 200^167^ | 0.018 (0.007, 0.042) | 98.4 | 280
Harris ELR, 2000^172^ | 0.062 (0.032, 0.114) | 85.2 | 146
Chan KC, 2001^159^ | 0.026 (0.002, 0.31) | 47 | 18
Fish EB, 1998^183^ | 0.026 (0.002, 0.31) | 60 | 18
Cutuli B, 2002^188^ | 0.078 (0.057, 0.104) | 84 | 515
Amichetti M, 1997^199^ | 0.043 (0.02, 0.093) | 81 | 139
Miller NA, 2001^203^ | 0.026 (0.002, 0.31) | 60 | 18
Ciatto S, 1990^214^ | 0.049 (0.02, 0.111) | 66 | 103
SahooS, 2005^216^ | 0.039 (0.015, 0.099) | 63 | 103
Solin LJ, 1996^221^ | 0.089 (0.06, 0.129) | 123.6 | 270
Fowble B, 1997^230^ | 0.027 (0.009, 0.081) | 63.6 | 110
Rodrigues N, 2004^233^ | 0.01 (0.001, 0.067) | 34 | 101
LR/local DCIS or invasive carcinoma recurrence per 100 patient-years at risk
Ciatto S, 1990^214^ | 0.014 | 66 | 103
West JG, 2007^260^ | 0.16 | 99 | 71
LR/regional recurrence
Fowble B, 1997^230^ | 0.005 (0, 0.068) | 63.6 | 110
Vapiwala N, 2006^219^ | 0.003 (0, 0.04) | 74.4 | 192
Cutuli B, 2002^188^ | 0.017 (0.009, 0.033) | 84 | 515
Amichetti M, 1997^199^ | 0.007 (0.001, 0.049) | 81 | 139
LR/contralateral DCIS or invasive carcinoma
Vapiwala N, 2006^219^ | 0.16 (0.06, 0.38) | 180 | 192
Solin LJ, 1996^221^ | 0.09 (0.04, 0.13) | 180 | 270
Meijnen P, 2008^211^ | 0 (0, 0) | 96 | 119
Cutuli B, 2002^188^ | 0.071 (0, 0) | 84 | 420
Vicini FA, 2001^180^ | 0.087 | 120 | 148
Harris ELR, 2000^172^ | 0.1 | 120 | 146
Jhingran A, 2002^251^ | 0.03 | 120 | 150
Adepoju LJ, 2006^204^ | 0.045 | 120 | 211
Rodrigues N, 2002^167^ | 0.05 | 120 | 280
Fowble B, 1997^230^ | 0.018 (0.005, 0.07) | 63.6 | 110
Amichetti M, 1997^199^ | 0.029 (0.011, 0.074) | 81 | 139
Mirza NQ, 2000^201^ | 0.083 (0.044, 0.151) | 132 in DCIS, 144 in DCIS with microinvasion | 109
LR/contralateral DCIS
Vicini FA, 2001^180^ | 0.007 | 120 | 148
Fowble B, 1997^230^ | 0.005 (0, 0.068) | 63.6 | 110
Amichetti M, 1997^199^ | 0.014 (0.004, 0.056) | 81 | 139
LR/contralateral invasive carcinoma
Vicini FA, 2001^180^ | 0.079 | 120 | 148
Fowble B, 1997^230^ | 0.018 (0.005, 0.07) | 63.6 | 110
Miller NA, 2001^203^ | 0.026 (0.002, 0.31) | 60 | 18
Amichetti M, 1997^199^ | 0.014 (0.004, 0.056) | 81 | 139

Table F42 Observational studies of control and systemic outcomes stratified by LRT

Author | Probability or Rate | Length of Followup | Number Active
LRT/local DCIS or invasive carcinoma recurrence
Chan KC, 2001^159^ | 0.111 (0.015, 0.5) | 47 | 9
LRT/local DCIS recurrence
Chan KC, 2001^159^ | 0.111 (0.015, 0.5) | 47 | 9
LRT/local invasive carcinoma recurrence
Chan KC, 2001^159^ | 0.05 (0.003, 0.475) | 47 | 9

Table F43 Observational studies of control and systemic outcomes stratified by LRT

Author | Probability or Rate | Length of Followup | Number Active
LRT/local DCIS or invasive carcinoma recurrence
Chan KC, 2001^159^ | 0.102 (0.043, 0.223) | 47 | 49
Holland PA, 1998^229^ | 0.122 (0.052, 0.261) | 35 | 41
LRT/local DCIS recurrence
Chan KC, 2001^159^ | 0.102 (0.043, 0.223) | 47 | 49
LRT/local invasive carcinoma recurrence
Chan KC, 2001^159^ | 0.01 (0.001, 0.141) | 47 | 49

Table F44 Observational studies of control and systemic outcomes stratified by SSM

Author | Probability or Rate | Length of Followup | Number Active
SSM/distant metastasis
Carlson GW, 2007^245^ | 0.009 (0.002, 0.035) | 82.3 | 223
SSM/local DCIS or invasive carcinoma recurrence
Carlson GW, 2007^245^ | 0.031 (0.015, 0.064) | 82.3 | 223
SSM/local DCIS recurrence
Carlson GW, 2007^245^ | 0.004 (0.001, 0.031) | 82.3 | 223
SSM/local invasive carcinoma recurrence
Carlson GW, 2007^245^ | 0.027 (0.012, 0.059) | 82.3 | 223
SSM/regional recurrence
Carlson GW, 2007^245^ | 0.009 (0.002, 0.035) | 82.3 | 223
SSM, type I/any recurrence
Carlson GW, 2007^245^ | 0.085 (0.041, 0.168) | 82.3 | 82
SSM, type I/local DCIS or invasive carcinoma recurrence
Carlson GW, 2007^245^ | 0.061 (0.026, 0.138) | 82.3 | 82
SSM, not type I/any recurrence
Carlson GW, 2007^245^ | 0.045 (0.017, 0.115) | 82.3 | 88
SSM, not type I/local DCIS or invasive carcinoma recurrence
Carlson GW, 2007^245^ | 0.023 (0.006, 0.086) | 82.3 | 88

Table F45 Observational studies of control and systemic outcomes stratified by lumpectomy + APBI

Author | Probability or Rate | Length of Followup | Number Active
L + APBI/breast infection
Jeruss JS, 2006^168^ | 0.032 (0.013, 0.074) | 7.35 | 158
Bemitez PR, 2006^234^ | 0.04 | 9.5 | 100
L + APBI/late radiation skin change
Jeruss JS, 2006^168^ | 0.089 (0.053, 0.144) | 7.35 | 158
L + APBI/pain
Jeruss JS, 2006^168^ | 0.234 (0.175, 0.306) | 7.35 | 158
L + APBI/seroma
Jeruss JS, 2006^168^ | 0.152 (0.104, 0.217) | 7.35 | 158
L + APBI/skin color change
Jeruss JS, 2006^168^ | 0.114 (0.073, 0.174) | 7.35 | 158
L + APBI/skin discoloration
Jeruss JS, 2006^168^ | 0.089 (0.053, 0.144) | 7.35 | 158
L + APBI/skin erythema
Jeruss JS, 2006^168^ | 0.108 (0.068, 0.166) | 7.35 | 158
L + APBI/subcutaneous tissue changes
Jeruss JS, 2006^168^ | 0.184 (0.131, 0.252) | 7.35 | 158
L + APBI/contralateral DCIS or invasive
Vicini FA, 2008^175^ | 0.006 | 24 | 195
L + APBI/cosmetic -percent of excellent
Bemitez PR, 2006^234^ | 0.63 | 9.5 | 100
L + APBI/cosmetic -percent of fair
Bemitez PR, 2006^234^ | 0.02 | 9.5 | 100
L + APBI/cosmetic -percent of good
Bemitez PR, 2006^234^ | 0.35 | 9.5 | 100
L + APBI/distant metastasis
Vicini FA, 2008^175^ | 0.006 | 24 | 195
L + APBI/breast cancer mortality
Vicini FA, 2008^175^ | 0.006 | 24 | 195
L + APBI/all causes mortality
Vicini FA, 2008^175^ | 0.013 | 28.6 | 195
L + APBI/local DCIS or invasive carcinoma recurrence
Vicini FA, 2008^175^ | 0 | 24 | 195
Bemitez PR, 2006, 16978943 | 0.02 (0.005, 0.076) | 9.5 | 100
Jeruss JS, 2006^168^ | 0.003 (0, 0.048) | 7.35 | 158
L + APBI/local DCIS recurrence
Bemitez PR, 2006^234^ | 0.02 (0.005, 0.076) | 9.5 | 100
L + APBI/local invasive carcinoma recurrence
Bemitez PR, 2006^234^ | 0.005 (0, 0.074) | 9.5 | 100
L + APBI/regional failure
Vicini FA, 2008^175^ | 0.005 (0.001, 0.035) | 28.6 | 195

## References for Appendix F

(Note that this set of references is different from those in the text of the report and the numbers are different.)

1 Houssami N, Ciatto S, Macaskill P, et al. Accuracy and surgical impact of magnetic resonance imaging in breast cancer staging: systematic review and meta-analysis in detection of multifocal and multicentric cancer. J Clin Oncol. Jul 1. 2008;26(19):3248-58. [pmid: 18474876].
2 Lewis JD, Milbrath JR, Shaffer KA, et al. Implications of suspicious findings in breast cancer screening. Arch Surg. Aug. 1975;110(8):903-7. [pmid: 168837].
3 Schwartz GF, Feig SA, Libshitz HI, et al. Mass screening for breast disease. Results, problems, and expectations. Obstet Gynecol. Aug. 1976;48(2):137-41. [pmid: 181701].
4 Feig SA, Shaber GS, Patchefsky A, et al. Analysis of clinically occult and mammographically occult breast tumors. AJR Am J Roentgenol. Mar. 1977;128(3):403-8. [pmid: 190908].
5 Patchefsky AS, Shaber GS, Schwartz GF, et al. The pathology of breast cancer detected by mass population screening. Cancer. Oct. 1977;40(4):1659-70. [pmid: 907976].
6 Croll J, MacMillan IS, Ryan J. Screening for breast cancer by mammography: an Australian experience. Med J Aust. Feb 26. 90. 1977;1(9):287-2. [pmid: 192986].
7 Kreger BE, Splansky GL, Schatzkin A. The cancer experience in the Framingham Heart Study cohort. Cancer. Jan 1. 1991;67(1):1-6. [pmid: 1845934].
8 Simon MS, Lemanne D, Schwartz AG, et al. Recent trends in the incidence of in situ and invasive breast cancer in the Detroit metropolitan area (1975–1988). Cancer. Feb 1. 1993;71(3):769-74. [pmid: 8431859].
9 Alves JG, Cruz DB, Rodrigues VL, et al. Breast cancer screening in the central region of Portugal. Eur J Cancer Prev. 01. 1994;3(Suppl 1):49-53. [pmid: 8130727].
10 Van Oyen H, Verellen W. Breast cancer screening in the Flemish region, Belgium. Eur J Cancer Prev. 01. 1994;3(Suppl 1):7-12. [pmid: 8130728].
11 Garas I, Pateras H, Triandafilou D, et al. Breast cancer screening in southern Greece. Eur J Cancer Prev. 01. 1994;3(Suppl 1):35-9. [pmid: 8130725].
12 Curpen BN, Sickles EA, Sollitto RA, et al. The comparative value of mammographic screening for women 40–49 years old versus women 50–64 years old. AJR Am J Roentgenol. May. 1995;164(5):1099-103. [pmid: 7717212].
13 Tabar L, Fagerberg G, Chen HH, et al. Efficacy of breast cancer screening by age. New results from the Swedish Two-County Trial. Cancer. 05. 15. 1995;75(10):2507-17. [pmid: 7736395].
14 Faulk RM, Sickles EA, Sollitto RA, et al. Clinical efficacy of mammographic screening in the elderly. Radiology. Jan. 1995;194(1):193-7. [pmid: 7997552].
15 Tabar L, Fagerberg G, Chen HH, et al. Tumour development, histology and grade of breast cancers: prognosis and progression. Int J Cancer. May 16. 1996;66(4):413-9. [pmid: 8635853].
16 Kerlikowske K, Grady D, Barclay J, et al. Effect of age, breast density, and family history on the sensitivity of first screening mammography. JAMA. Jul 3. 1996;276(1):33-8. [pmid: 8667536].
17 Zheng T, Holford TR, Chen Y, et al. Time trend of female breast carcinoma in situ by race and histology in Connecticut, USA. Eur J Cancer. Jan. 1997;33(1):96-100. [pmid: 9071907].
18 Evans WP 3rd, Starr AL, Bennos ES. Comparison of the relative incidence of impalpable invasive breast carcinoma and ductal carcinoma in situ in cancers detected in patients older and younger than 50 years of age. Radiology. Aug. 1997;204(2):489-91. [pmid: 9240541].
19 Levi F, Te VC, Randimbison L, et al. Trends of in situ carcinoma of the breast in Vaud, Switzerland. Eur J Cancer. May. 1997;33(6):903-6. [pmid: 9291813].
20 Vizcaino I, Salas D, Vilar JS, et al. Breast cancer screening: first round in the population-based program in Valencia, Spain. Collaborative Group of Readers of the Breast Cancer Screening Program of the Valencia Community. Radiology. Jan. 1998;206(1):253-60. [pmid: 9423680].
21 Chan LK, Lam HS, Chan ES, et al. Mammogram screening of Chinese women in Kwong Wah Hospital, Hong Kong. Australas Radiol. Feb. 1998;42(1):6-9. [pmid: 9509595].
22 Dershaw DD, Loring L, True SJ, et al. A comparison of screening mammography results from programs for women of different socioeconomic status. Cancer. May 1. 1998;82(9):1692-7. [pmid: 9576290].
23 Fracheboud J, de Koning HJ, Beemsterboer PM, et al. Nation-wide breast cancer screening in The Netherlands: results of initial and subsequent screening 1990–1995. National Evaluation Team for Breast Cancer Screening. Int J Cancer. Mar 2. 1998;75(5):694-8. [pmid: 9495236].
24 Kitchen PR, Cawson JN, Winch KL, et al. Characteristics and treatment of breast cancers 10 mm or less detected by a mammographic screening programme. Aust N Z J Surg. Jan. 1998;68(1):45-9. [pmid: 9440456].
25 Warren R, Duffy S. Interval cancers as an indicator of performance in breast screening. Breast Cancer. Jan. 2000;7(1):9-18. [pmid: 11029765].
26 Barchielli A, Paci E, Giorgi D. Recent trends of in situ carcinoma of the breast and mammographic screening in the Florence area, Italy. Cancer Causes Control. Aug. 1999;10(4):313-7. [pmid: 10482490].
27 Kerlikowske K, Carney PA, Geller B, et al. Performance of screening mammography among women with and without a first-degree relative with breast cancer. Ann Intern Med. Dec 5. 2000;133(11):855-63. [pmid: 11103055].
28 Walter LC, Eng C, Covinsky KE. Screening mammography for frail older women: what are the burdens?. J Gen Intern Med. Nov. 2001;16(11):779-84. [pmid: 11722693].
29 Innos K, Horn-Ross PL. Recent trends and racial/ethnic differences in the incidence and treatment of ductal carcinoma in situ of the breast in California women. Cancer. Feb 15. 2003;97(4):1099-106. [pmid: 12569612].
30 Ernster VL, Ballard-Barbash R, Barlow WE, et al. Detection of ductal carcinoma in situ in women undergoing screening mammography. J Natl Cancer Inst. Oct 16. 2002;94(20):1546-54. [pmid: 12381707].
31 Schootman M, Kinman E, Farria D. Rural-urban differences in ductal carcinoma in situ as a proxy for mammography use over time. J Rural Health. Fall. 2003;19(4):470-6. [pmid: 14526505].
32 Smith-Bindman R, Chu PW, Miglioretti DL, et al. Comparison of screening mammography in the United States and the United kingdom. JAMA. Oct 22. 2003;290(16):2129-37. [pmid: 14570948].
33 Baxter NN, Virnig BA, Durham SB, et al. Trends in the treatment of ductal carcinoma in situ of the breast. J Natl Cancer Inst. Mar 17. 2004;96(6):443-8. [pmid: 15026469].
34 Coburn NG, Chung MA, Fulton J, et al. Decreased breast cancer tumor size, stage, and mortality in Rhode Island: an example of a well-screened population. Cancer Control. Jul–Aug. 2004;11(4):222-30. [pmid: 15284713].
35 Anderson WF, Chu KC, Devesa SS. Distinct incidence patterns among in situ and invasive breast carcinomas, with possible etiologic implications. Breast Cancer Res Treat. Nov. 2004;88(2):149-59. [pmid: 15564798].
36 Fracheboud J, Otto SJ, van Dijck JA, et al. Decreased rates of advanced breast cancer due to mammography screening in The Netherlands. Br J Cancer. 08. 31. 2004;91(5):861-7. [pmid: 15292936].
37 Erbas B, Amos A, Fletcher A, et al. Incidence of invasive breast cancer and ductal carcinoma in situ in a screening program by age: should older women continue screening?. Cancer Epidemiol Biomarkers Prev. Oct. 2004;13(10):1569-73. [pmid: 15466971].
38 Kricker A, Goumas C, Armstrong B. Ductal carcinoma in situ of the breast, a population-based study of epidemiology and pathology. Br J Cancer. Apr 5. 2004;90(7):1382-5. [pmid: 15054459].
39 Barchielli A, Federico M, De Lisi V, et al. In situ breast cancer: incidence trend and organised screening programmes in Italy. Eur J Cancer. May. 2005;41(7):1045-50. [pmid: 15862754].
40 Blanks RG, Bennett RL, Patnick J, et al. The effect of changing from one to two views at incident (subsequent) screens in the NHS breast screening programme in England: impact on cancer detection and recall rates. Clin Radiol. 06. 2005;60(6):674-80. [pmid: 16038694].
41 Leach MO, Boggis CR, Dixon AK, et al. Screening with magnetic resonance imaging and mammography of a UK population at high familial risk of breast cancer: a prospective multicentre cohort study (MARIBS). Lancet. May 21–27. 2005;365(9473):1769-78. [pmid: 15910949].
42 Birdwell RL, Bandodkar P, Ikeda DM. Computer-aided detection with screening mammography in a university hospital setting. Radiology. Aug. 2005;236(2):451-7. [pmid: 16040901].
43 Kumar AS, Bhatia V, Henderson IC. Overdiagnosis and overtreatment of breast cancer: rates of ductal carcinoma in situ: a US perspective. Breast Cancer Res. 2005;7(6):271-5. [pmid: 16457703].
44 Li CI, Daling JR, Malone KE. Age-specific incidence rates of in situ breast carcinomas by histologic type, 1980 to 2001. Cancer Epidemiol Biomarkers Prev. Apr. 2005;14(4):1008-11. [pmid: 15824180].
45 Smith-Bindman R, Ballard-Barbash R, Miglioretti DL, et al. Comparing the performance of mammography screening in the USA and the UK. J Med Screen. 2005;12(1):50-4. [pmid: 15814020].
46 Weaver DL, Vacek PM, Skelly JM, et al. Predicting biopsy outcome after mammography: what is the likelihood the patient has invasive or in situ breast cancer?. Ann Surg Oncol. Aug. 2005;12(8):660-73. [pmid: 15968496].
47 Kerlikowske K, Creasman J, Leung JW, et al. Differences in screening mammography outcomes among White, Chinese, and Filipino women. Arch Intern Med. Sep 12. 2005;165(16):1862-8. [pmid: 16157830].
48 Duffy SW, Agbaje O, Tabar L, et al. Overdiagnosis and overtreatment of breast cancer: estimates of overdiagnosis from two trials of mammographic screening for breast cancer. Breast Cancer Res. 2005;7(6):258-65. [pmid: 16457701].
49 Nekhlyudov L, Kroenke CH, Jung I, et al. Prospective changes in quality of life after ductal carcinoma-in-situ: results from the Nurses’ Health Study. J Clin Oncol. Jun 20. 2006;24(18):2822-7. [pmid: 16782920].
50 Boncz I, Sebestyen A, Dobrossy L, et al. The organisation and results of first screening round of the Hungarian nationwide organised breast cancer screening programme. Ann Oncol. Apr. 2007;18(4):795-9. [pmid: 17259642].
51 Gill JK, Maskarinec G, Pagano I, et al. The association of mammographic density with ductal carcinoma in situ of the breast: the Multiethnic Cohort. Breast Cancer Res. 2006;8(3):R30. [pmid: 16796758].
52 Weaver DL, Rosenberg RD, Barlow WE, et al. Pathologic findings from the Breast Cancer Surveillance Consortium: population-based outcomes in women undergoing biopsy after screening mammography. Cancer. Feb 15. 2006;106(4):732-42. [pmid: 16411214].
53 Rakovitch E, Pignol JP, Chartier C, et al. The management of ductal carcinoma in situ of the breast: a screened population-based analysis. Breast Cancer Res Treat. Mar. 2007;101(3):335-47. [pmid: 16838110].
54 Yeoh KG, Chew L, Wang SC. Cancer screening in Singapore, with particular reference to breast, cervical and colorectal cancer screening. J Med Screen. 2006;13(Suppl 1):S14-9. [pmid: 17227636].
55 Moran CJ, Kell MR, Flanagan FL, et al. Role of sentinel lymph node biopsy in high-risk ductal carcinoma in situ patients. Am J Surg. Aug. 2007;194(2):172-5. [pmid: 17618799].
56 Sumner WE 3rd, Koniaris LG, Snell SE, et al. Results of 23,810 cases of ductal carcinoma-in-situ. Ann Surg Oncol. May. 2007;14(5):1638-43. [pmid: 17245612].
57 Kerlikowske K, Miglioretti DL, Buist DS, et al. Declines in invasive breast cancer and use of postmenopausal hormone therapy in a screening mammography population. J Natl Cancer Inst. Sep 5. 2007;99(17):1335-9. [pmid: 17698950].
58 MacKenzie TA, Titus-Ernstoff L, Vacek PM, et al. Breast density in relation to risk of ductal carcinoma in situ of the breast in women undergoing screening mammography. Cancer Causes Control. Nov. 2007;18(9):939-45. [pmid: 17638106].
59 Kerlikowske K, Ichikawa L, Miglioretti DL, et al. Longitudinal measurement of clinical mammographic breast density to improve estimation of breast cancer risk. J Natl Cancer Inst. Mar 7. 2007;99(5):386-95. [pmid: 17341730].
60 Tuncbilek I, Ozdemir A, Gultekin S, et al. Clinical outcome assessment in mammography: an audit of 7,506 screening and diagnostic mammography examinations. Diagn Interv Radiol. Dec. 2007;13(4):183-7. [pmid: 18092288].
61 Hofvind S, Sorum R, Thoresen S. Incidence and tumor characteristics of breast cancer diagnosed before and after implementation of a population-based screening-program. Acta Oncol. 2008;47(2):225-31. [pmid: 17851868].
62 Yu J, Park A, Morris E, et al. MRI screening in a clinic population with a family history of breast cancer. Ann Surg Oncol. Feb. 2008;15(2):452-61. [pmid: 18026801].
63 Vigeland E, Klaasen H, Klingen TA, et al. Full-field digital mammography compared to screen film mammography in the prevalent round of a population-based screening programme: the Vestfold County Study. Eur Radiol. Jan. 2008;18(1):183-91. [pmid: 17680246].
64 Weiss HA, Brinton LA, Brogan D, et al. Epidemiology of in situ and invasive breast cancer in women aged under 45. Br J Cancer. May. 1996;73(10):1298-305. [pmid: 8630296].
65 Kerlikowske K, Barclay J, Grady D, et al. Comparison of risk factors for ductal carcinoma in situ and invasive breast cancer. J Natl Cancer Inst. Jan 1. 1997;89(1):76-82. [pmid: 8978410].
66 Elmore JG, Moceri VM, Carter D, et al. Breast carcinoma tumor characteristics in black and white women. Cancer. Dec 15. 1998;83(12):2509-15. [pmid: 9874456].
67 Elkhadrawy TM, Ahsan H, Neugut AI. Serum cholesterol and the risk of ductal carcinoma in situ: a case-control study. Eur J Cancer Prev. Oct. 1998;7(5):393-6. [pmid: 9884885].
68 Bohlke K, Cramer DW, Trichopoulos D, et al. Insulin-like growth factor-I in relation to premenopausal ductal carcinoma in situ of the breast. Epidemiology. Sep. 1998;9(5):570-3. [pmid: 9730040].
69 Gapstur SM, Morrow M, Sellers TA. Hormone replacement therapy and risk of breast cancer with a favorable histology: results of the Iowa Women’s Health Study. JAMA. Jun 9. 1999;281(22):2091-7. [pmid: 10367819].
70 Trentham-Dietz A, Newcomb PA, Storer BE, et al. Risk factors for carcinoma in situ of the breast. Cancer Epidemiol Biomarkers Prev. Jul. 2000;9(7):697-703. [pmid: 10919740].
71 Claus EB, Stowe M, Carter D. Breast carcinoma in situ: risk factors and screening patterns. J Natl Cancer Inst. Dec 5. 2001;93(23):1811-7. [pmid: 11734598].
72 Cuzick J, Forbes J, Edwards R, et al. First results from the International Breast Cancer Intervention Study (IBIS-I): a randomised prevention trial. Lancet. Sep 14. 2002;360(9336):817-24. [pmid: 12243915].
73 Frank TS, Deffenbaugh AM, Reid JE, et al. Clinical characteristics of individuals with germline mutations in BRCA1 and BRCA2: analysis of 10,000 individuals. J Clin Oncol. Mar 15. 2002;20(6):1480-90. [pmid: 11896095].
74 Johnson TW, Anderson KE, Lazovich D, et al. Association of Aspirin and Nonsteroidal Anti-inflammatory Drug Use. Cancer Epidemiology, Biomarkers & Prevention. 2007;11:1586-91.
75 Claus EB, Stowe M, Carter D. Family history of breast and ovarian cancer and the risk of breast carcinoma in situ. Breast Cancer Res Treat. Mar. 2003;78(1):7-15. [pmid: 12611452].
76 Claus EB, Stowe M, Carter D. Oral contraceptives and the risk of ductal breast carcinoma in situ. Breast Cancer Res Treat. Sep. 2003;81(2):129-36. [pmid: 14572155].
77 Kerlikowske K, Miglioretti DL, Ballard-Barbash R, et al. Prognostic characteristics of breast cancer among postmenopausal hormone users in a screened population. J Clin Oncol. Dec 1. 2003;21(23):4314-21. [pmid: 14645420].
78 Patel AV, Press MF, Meeske K, et al. Lifetime recreational exercise activity and risk of breast carcinoma in situ. Cancer. Nov 15. 2003;98(10):2161-9. [pmid: 14601085].
79 Wohlfahrt J, Rank F, Kroman N, et al. A comparison of reproductive risk factors for CIS lesions and invasive breast cancer. Int J Cancer. Feb 20. 2004;108(5):750-3. [pmid: 14696102].
80 Zeleniuch-Jacquotte A, Gu Y, Shore RE, et al. Postmenopausal levels of sex hormones and risk of breast carcinoma in situ: results of a prospective study. Int J Cancer. Mar 20. 2005;114(2):323-7. [pmid: 15540225].
81 Reeves GK, Beral V, Green J, et al. Hormonal therapy for menopause and breast-cancer risk by histological type: a cohort study and meta-analysis. Lancet Oncol. Nov. 2006;7(11):910-8. [pmid: 17081916].
82 Chen CY, Sun LM, Anderson BO. Paget disease of the breast: changing patterns of incidence, clinical presentation, and treatment in the U.S. Cancer. Oct 1. 2006;107(7):1448-58. [pmid: 16933329].
83 Vamre TB, Stalsberg H, Thomas DB. Extra-tumoral breast tissue in breast cancer patients: variations with steroid contraceptive use. Int J Cancer. Jun 1. 2006;118(11):2827-31. [pmid: 16380999].
84 Cuzick J, Forbes JF, Sestak I, et al. Long-term results of tamoxifen prophylaxis for breast cancer--96-month follow-up of the randomized IBIS-I trial. J Natl Cancer Inst. Feb 21. 2007;99(4):272-82. [pmid: 17312304].
85 Powles TJ, Ashley S, Tidy A, et al. Twenty-year follow-up of the Royal Marsden randomized, double-blinded tamoxifen breast cancer prevention trial. J Natl Cancer Inst. Feb 21. 2007;99(4):283-90. [pmid: 17312305].
86 Nichols HB, Trentham-Dietz A, Egan KM, et al. Oral contraceptive use and risk of breast carcinoma in situ. Cancer Epidemiol Biomarkers Prev. Nov. 2007;16(11):2262-8. [pmid: 18006914].
87 Stacey SN, Manolescu A, Sulem P, et al. Common variants on chromosome 5p12 confer susceptibility to estrogen receptor-positive breast cancer. Nat Genet. Jun. 2008;40(6):703-6. [pmid: 18438407].
88 Granstrom C, Sundquist J, Hemminki K. Population attributable risks for breast cancer in Swedish women by morphological type. Breast Cancer Research & Treatment. Oct. 2008;111(3):559-68. [pmid: 17990099].
89 Brekelmans CT, Seynaeve C, Bartels CC, et al. Effectiveness of breast cancer surveillance in BRCA1/2 gene mutation carriers and women with high familial risk. J Clin Oncol. Feb 15. 2001;19(4):924-30. [pmid: 11181654].
90 Saetersdal A, Dorum A, Heimdal K, et al. Inherited predisposition to breast carcinoma. Results of first round examination of 537 women at risk. Anticancer Res. Jul-Aug. 1996;16(4A):1989-92. [pmid: 8712731].
91 Moller P, Maehle L, Heimdal K, et al. Inherited breast carcinoma--prospective findings in 1,194 women at risk. Acta Oncol. 1996;35(Suppl 8):7-11. [pmid: 9073043].
92 Chart PL, Franssen E. Management of women at increased risk for breast cancer: preliminary results from a new program. Cmaj. Nov 1. 1997;157(9):1235-42. [pmid: 9361645].
93 Lalloo F, Boggis CR, Evans DG, et al. Screening by mammography, women with a family history of breast cancer. Eur J Cancer. May. 1998;34(6):937-40. [pmid: 9797712].
94 Kollias J, Sibbering DM, Blamey RW, et al. Screening women aged less than 50 years with a family history of breast cancer. Eur J Cancer. May. 1998;34(6):878-83. [pmid: 9797701].
95 Tilanus-Linthorst MM, Bartels CC, Obdeijn AI, et al. Earlier detection of breast cancer by surveillance of women at familial risk. Eur J Cancer. Mar. 2000;36(4):514-9. [pmid: 10717529].
96 Brekelmans CT, Westers P, Faber JA, et al. Age specific sensitivity and sojourn time in a breast cancer screening programme (DOM) in The Netherlands: a comparison of different methods. J Epidemiol Community Health. Feb. 1996;50(1):68-71. [pmid: 8762357].
97 Komenaka IK, Ditkoff BA, Joseph KA, et al. The development of interval breast malignancies in patients with BRCA mutations. Cancer. May 15. 2004;100(10):2079-83. [pmid: 15139048].
98 Hoogerbrugge N, Bult P, Bonenkamp JJ, et al. Numerous high-risk epithelial lesions in familial breast cancer. Eur J Cancer. Oct. 2006;42(15):2492-8. [pmid: 16908132].
99 Hagen AI, Kvistad KA, Maehle L, et al. Sensitivity of MRI versus conventional screening in the diagnosis of BRCA-associated breast cancer in a national prospective series. Breast. Aug. 2007;16(4):367-74. [pmid: 17317184].
100 Kuhl CK, Schmutzler RK, Leutner CC, et al. Breast MR imaging screening in 192 women proved or suspected to be carriers of a breast cancer susceptibility gene: preliminary results. Radiology. Apr. 2000;215(1):267-79. [pmid: 10751498].
101 Warner E, Plewes DB, Shumak RS, et al. Comparison of breast magnetic resonance imaging, mammography, and ultrasound for surveillance of women at high risk for hereditary breast cancer. J Clin Oncol. Aug 1. 2001;19(15):3524-31. [pmid: 11481359].
102 Podo F, Sardanelli F, Canese R, et al. The Italian multi-centre project on evaluation of MRI and other imaging modalities in early detection of breast cancer in subjects at high genetic risk. J Exp Clin Cancer Res. Sep. 2002;21(3 Suppl):115-24. [pmid: 12585665].
103 Kriege M, Brekelmans CT, Boetes C, et al. Efficacy of MRI and mammography for breast-cancer screening in women with a familial or genetic predisposition. N Engl J Med. Jul 29. 2004;351(5):427-37. [pmid: 15282350].
104 Warner E, Plewes DB, Hill KA, et al. Surveillance of BRCA1 and BRCA2 mutation carriers with magnetic resonance imaging, ultrasound, mammography, and clinical breast examination. JAMA. Sep 15. 2004;292(11):1317-25. [pmid: 15367553].
105 Hartman AR, Daniel BL, Kurian AW, et al. Breast magnetic resonance image screening and ductal lavage in women at high genetic risk for breast carcinoma. Cancer. Feb 1. 2004;100(3):479-89. [pmid: 14745863].
106 Chung A, Saouaf R, Scharre K, et al. The impact of MRI on the treatment of DCIS. Am Surg. Sep. 2005;71(9):705-10. [pmid: 16468502].
107 Solin LJ, Orel SG, Hwang WT, et al. Relationship of breast magnetic resonance imaging to outcome after breast-conservation treatment with radiation for women with early-stage invasive breast carcinoma or ductal carcinoma in situ. J Clin Oncol. Jan 20. 2008;26(3):386-91. [pmid: 18202414].
108 Hwang ES, Kinkel K, Esserman LJ, et al. Magnetic resonance imaging in patients diagnosed with ductal carcinoma-in-situ: value in the diagnosis of residual disease, occult invasion, and multicentricity. Ann Surg Oncol. May. 2003;10(4):381-8. [pmid: 12734086].
109 Tillman GF, Orel SG, Schnall MD, et al. Effect of breast magnetic resonance imaging on the clinical management of women with early-stage breast carcinoma. J Clin Oncol. Aug 15. 2002;20(16):3413-23. [pmid: 12177101].
110 Bluemke DA, Gatsonis CA, Chen MH, et al. Magnetic resonance imaging of the breast prior to biopsy. JAMA. Dec 8. 2004;292(22):2735-42. [pmid: 15585733].
111 Kuhl CK, Schrading S, Bieling HB, et al. MRI for diagnosis of pure ductal carcinoma in situ: a prospective observational study. Lancet. Aug 11. 2007;370(9586):485-92. [pmid: 17693177].
112 Lehman CD, Gatsonis C, Kuhl CK, et al. MRI evaluation of the contralateral breast in women with recently diagnosed breast cancer. N Engl J Med. Mar 29. 2007;356(13):1295-303. [pmid: 17392300].
113 Hollingsworth AB, Stough RG, O’Dell CA, et al. Breast magnetic resonance imaging for preoperative locoregional staging. Am J Surg. Sep. 2008;196(3):389-97. [pmid: 18436185].
114 Menell JH, Morris EA, Dershaw DD, et al. Determination of the presence and extent of pure ductal carcinoma in situ by mammography and magnetic resonance imaging. Breast J. Nov–Dec. 2005;11(6):382-90. [pmid: 16297080].
115 Brem RF, Fishman M, Rapelyea JA. Detection of ductal carcinoma in situ with mammography, breast specific gamma imaging, and magnetic resonance imaging: a comparative study. Acad Radiol. Aug. 2007;14(8):945-50. [pmid: 17659240].
116 Uematsu T, Yuen S, Kasami M, et al. Comparison of magnetic resonance imaging, multidetector row computed tomography, ultrasonography, and mammography for tumor extension of breast cancer. Breast Cancer Research & Treatment. Dec. 2008;112(3):461-74. [pmid: 18193352].
117 Houserkova D, Prasad SN, Svach I, et al. The value of dynamic contrast enhanced breast MRI in mammographically detected BI-RADS 5 microcalcifications. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub. Jun. 2008;152(1):107-15. [pmid: 18795084].
118 Onesti JK, Mangus BE, Helmer SD, et al. Breast cancer tumor size: correlation between magnetic resonance imaging and pathology measurements. Am J Surg. Dec. 2008;196(6:):844-48. discussion 9–50. [pmid: 19095098].
119 Santamaria G, Velasco M, Farrus B, et al. Preoperative MRI of pure intraductal breast carcinoma--a valuable adjunct to mammography in assessing cancer extent. Breast. Apr. 2008;17(2):186-94. [pmid: 17964786].
120 Pediconi F, Venditti F, Padula S, et al. CE-Magnetic Resonance Mammography for the evaluation of the contralateral breast in patients with diagnosed breast cancer. Radiol Med (Torino). Jul–Aug. 2005;110:1-2. 61. 8. [pmid: 16163136].
121 Liberman L, Morris EA, Kim CM, et al. MR imaging findings in the contralateral breast of women with recently diagnosed breast cancer. AJR Am J Roentgenol. Feb. 2003;180(2):333-41. [pmid: 12540428].
122 Schouten van der Velden AP, Boetes C, Bult P, et al. The value of magnetic resonance imaging in diagnosis and size assessment of in situ and small invasive breast carcinoma. Am J Surg. Aug. 2006;192(2):172-8. [pmid: 16860625].
123 Hollingsworth AB, Stough RG. Preoperative breast MRI for locoregional staging. J Okla State Med Assoc. Oct. 2006;99(10):505-15. [pmid: 17125104].
124 Schelfout K, Van Goethem M, Kersschot E, et al. Contrast-enhanced MR imaging of breast lesions and effect on treatment. Eur J Surg Oncol. Jun. 2004;30(5):501-7. [pmid: 15135477].
125 Zhang Y, Fukatsu H, Naganawa S, et al. The role of contrast-enhanced MR mammography for determining candidates for breast conservation surgery. Breast Cancer. 2002;9(3):231-9. [pmid: 12185335].
126 Intra M, Rotmensz N, Veronesi P, et al. Sentinel node biopsy is not a standard procedure in ductal carcinoma in situ of the breast: the experience of the European institute of oncology on 854 patients in 10 years. Ann Surg. Feb. 2008;247(2):315-9. [pmid: 18216539].
127 Intra M, Veronesi P, Mazzarol G, et al. Axillary sentinel lymph node biopsy in patients with pure ductal carcinoma in situ of the breast. Arch Surg. Mar. 2003;138(3):309-13. [pmid: 12611580].
128 Huo L, Sneige N, Hunt KK, et al. Predictors of invasion in patients with core-needle biopsy-diagnosed ductal carcinoma in situ and recommendations for a selective approach to sentinel lymph node biopsy in ductal carcinoma in situ. Cancer. Oct 15. 2006;107(8):1760-8. [pmid: 16977650].
129 Polom K, Murawa D, Wasiewicz J, et al. The role of sentinel node biopsy in ductal carcinoma in situ of the breast. Eur J Surg Oncol. 2008. Aug 22.
130 Dominguez FJ, Golshan M, Black DM, et al. Sentinel node biopsy is important in mastectomy for ductal carcinoma in situ. Ann Surg Oncol. Jan. 2008;15(1):268-73. [pmid: 17891441].
131 Mabry H, Giuliano AE, Silverstein MJ. What is the value of axillary dissection or sentinel node biopsy in patients with ductal carcinoma in situ?. Am J Surg. Oct. 2006;192(4):455-7. [pmid: 16978948].
132 Tunon-de-Lara C, Giard S, Buttarelli M, et al. Sentinel node procedure is warranted in ductal carcinoma in situ with high risk of occult invasive carcinoma and microinvasive carcinoma treated by mastectomy. Breast J. Mar–Apr. 2008;14(2):135-40. [pmid: 18315691].
133 Sakr R, Antoine M, Barranger E, et al. Value of sentinel lymph node biopsy in breast ductal carcinoma in situ upstaged to invasive carcinoma. Breast J. Jan–Feb. 2008;14(1):55-60. [pmid: 18186866].
134 Yen TW, Hunt KK, Ross MI, et al. Predictors of invasive breast cancer in patients with an initial diagnosis of ductal carcinoma in situ: a guide to selective use of sentinel lymph node biopsy in management of ductal carcinoma in situ. J Am Coll Surg. Apr. 2005;200(4):516-26. [pmid: 15804465].
135 Sakr R, Barranger E, Antoine M, et al. Ductal carcinoma in situ: value of sentinel lymph node biopsy. J Surg Oncol. Oct 1. 2006;94(5):426-30. [pmid: 16967457].
136 Katz A, Gage I, Evans S, et al. Sentinel lymph node positivity of patients with ductal carcinoma in situ or microinvasive breast cancer. Am J Surg. Jun. 2006;191(6):761-6. [pmid: 16720145].
137 Klauber-DeMore N, Tan LK, Liberman L, et al. Sentinel lymph node biopsy: is it indicated in patients with high-risk ductal carcinoma-in-situ and ductal carcinoma-in-situ with microinvasion?. Ann Surg Oncol. Oct. 2000;7(9):636-42. [pmid: 11034239].
138 Tan JC, McCready DR, Easson AM, et al. Role of sentinel lymph node biopsy in ductal carcinoma-in-situ treated by mastectomy. Ann Surg Oncol. Feb. 2007;14(2):638-45. [pmid: 17103256].
139 Moore KH, Sweeney KJ, Wilson ME, et al. Outcomes for women with ductal carcinoma-in-situ and a positive sentinel node: a multi-institutional audit. Ann Surg Oncol. Oct. 2007;14(10):2911-7. [pmid: 17597346].
140 Veronesi P, Intra M, Vento AR, et al. Sentinel lymph node biopsy for localised ductal carcinoma in situ?. Breast. Dec. 2005;14(6):520-2. [pmid: 16185871].
141 Mittendorf EA, Arciero CA, Gutchell V, et al. Core biopsy diagnosis of ductal carcinoma in situ: an indication for sentinel lymph node biopsy. Curr Surg. Mar–Apr. 2005;62(2):253-7. [pmid: 15796952].
142 Gray RJ, Mulheron B, Pockaj BA, et al. The optimal management of the axillae of patients with microinvasive breast cancer in the sentinel lymph node era. Am J Surg. Dec. 2007;194(6:):845-8. discussion 8–9. [pmid: 18005782].
143 van la Parra RF, Ernst MF, Barneveld PC, et al. The value of sentinel lymph node biopsy in ductal carcinoma in situ (DCIS) and DCIS with microinvasion of the breast. Eur J Surg Oncol. Jun. 2008;34(6):631-5. [pmid: 17851019].
144 Camp R, Feezor R, Kasraeian A, et al. Sentinel lymph node biopsy for ductal carcinoma in situ: an evolving approach at the University of Florida. Breast J. Nov–Dec. 2005;11(6):394-7. [pmid: 16297082].
145 Zavagno G, Belardinelli V, Marconato R, et al. Sentinel lymph node metastasis from mammary ductal carcinoma in situ with microinvasion. Breast. Apr. 2007;16(2):146-51. [pmid: 17046258].
146 Intra M, Zurrida S, Maffini F, et al. Sentinel lymph node metastasis in microinvasive breast cancer. Ann Surg Oncol. Dec. 2003;10(10):1160-5. [pmid: 14654471].
147 Liu CL, Yang TL, Chen BF. Sentinel lymph node mapping with emulsion of activated carbon particles in patients with pre-mastectomy diagnosis of intraductal carcinoma of the breast. J Chin Med Assoc. Jul. 2003;66(7):406-10. [pmid: 14509402].
148 Tamhane R, Dahlstrom JE, McCallum DD, et al. The clinical significance of cytokeratin-positive cells in lymph nodes at the time of mastectomy from patients with ductal carcinoma-in-situ. Ann Surg Oncol. Dec. 2002;9(10):999-1003. [pmid: 12464593].
149 Zavotsky J, Hansen N, Brennan MB, et al. Lymph node metastasis from ductal carcinoma in situ with microinvasion. Cancer. Jun 1. 1999;85(11):2439-43. [pmid: 10357415].
150 Guth AA, Mercado C, Roses DF, et al. Microinvasive breast cancer and the role of sentinel node biopsy: an institutional experience and review of the literature. Breast J. Jul–Aug. 2008;14(4):335-9. [pmid: 18537917].
151 Smith BD, Haffty BG, Buchholz TA, et al. Effectiveness of radiation therapy in older women with ductal carcinoma in situ. J Natl Cancer Inst. Sep 20. 2006;98(18):1302-10. [pmid: 16985249].
152 Solin LJ, Fourquet A, Vicini FA, et al. Long-term outcome after breast-conservation treatment with radiation for mammographically detected ductal carcinoma in situ of the breast. Cancer. Mar 15. 2005;103(6):1137-46. [pmid: 15674853].
153 Wong JS, Kaelin CM, Troyan SL, et al. Prospective study of wide excision alone for ductal carcinoma in situ of the breast. J Clin Oncol. Mar 1. 2006;24(7):1031-6. [pmid: 16461781].
154 Bonnier P, Body G, Bessenay F, et al. Prognostic factors in ductal carcinoma in situ of the breast: results of a retrospective study of 575 cases. The Association for Research in Oncologic Gynecology. Eur J Obstet Gynecol Reprod Biol. May. 1999;84(1):27-35. [pmid: 10413223].
155 Tunon-de-Lara C, de-Mascarel I, Mac-Grogan G, et al. Analysis of 676 cases of ductal carcinoma in situ of the breast from 1971 to 1995: diagnosis and treatment--the experience of one institute. Am J Clin Oncol. Dec. 2001;24(6):531-6. [pmid: 11801749].
156 de Mascarel I, Bonichon F, MacGrogan G, et al. Application of the van nuys prognostic index in a retrospective series of 367 ductal carcinomas in situ of the breast examined by serial macroscopic sectioning: practical considerations. Breast Cancer Res Treat. May. 2000;61(2):151-9. [pmid: 10942101].
157 Cornfield DB, Palazzo JP, Schwartz GF, et al. The prognostic significance of multiple morphologic features and biologic markers in ductal carcinoma in situ of the breast: a study of a large cohort of patients treated with surgery alone. Cancer. Jun 1. 2004;100(11):2317-27. [pmid: 15160334].
158 Neuschatz AC, DiPetrillo T, Safaii H, et al. Margin width as a determinant of local control with and without radiation therapy for ductal carcinoma in situ (DCIS) of the breast. Int J Cancer. 2001;96(Suppl):97-104. [pmid: 11992392].
159 Chan KC, Knox WF, Sinha G, et al. Extent of excision margin width required in breast conserving surgery for ductal carcinoma in situ. Cancer. Jan 1. 2001;91(1):9-16. [pmid: 11148554].
160 Cutuli B, Cohen-Solal-Le Nir C, De Lafontan B, et al. Ductal carcinoma in situ of the breast results of conservative and radical treatments in 716 patients. Eur J Cancer. Dec. 2001;37(18):2365-72. [pmid: 11720829].
161 Joslyn SA. Ductal carcinoma in situ: trends in geographic, temporal, and demographic patterns of care and survival. Breast J. Jan–Feb. 2006;12(1):20-7. [pmid: 16409583].
162 Silverstein MJ. The University of Southern California/Van Nuys prognostic index for ductal carcinoma in situ of the breast. Am J Surg. Oct. 2003;186(4):337-43. [pmid: 14553846].
163 Schouten van der Velden AP, van Vugt R, Van Dijck JA, et al. Local recurrences after different treatment strategies for ductal carcinoma in situ of the breast: a population-based study in the East Netherlands. Int J Radiat Oncol Biol Phys. Nov 1. 2007;69(3):703-10. [pmid: 17544591].
164 Warren JL, Weaver DL, Bocklage T, et al. The frequency of ipsilateral second tumors after breast-conserving surgery for DCIS: a population based analysis. Cancer. Nov 1. 2005;104(9):1840-8. [pmid: 16136599].
165 Smith GL, Smith BD, Haffty BG. Rationalization and regionalization of treatment for ductal carcinoma in situ of the breast. Int J Radiat Oncol Biol Phys. Aug 1. 2006;65(5):1397-403. [pmid: 16750316].
166 Kerlikowske K, Molinaro A, Cha I, et al. Characteristics associated with recurrence among women with ductal carcinoma in situ treated by lumpectomy. J Natl Cancer Inst. Nov 19. 2003;95(22):1692-702. [pmid: 14625260].
167 Rodrigues N, Carter D, Dillon D, et al. Correlation of clinical and pathologic features with outcome in patients with ductal carcinoma in situ of the breast treated with breast-conserving surgery and radiotherapy. Int J Radiat Oncol Biol Phys. Dec 1. 2002;54(5):1331-5. [pmid: 12459354].
168 Jeruss JS, Vicini FA, Beitsch PD, et al. Initial outcomes for patients treated on the American Society of Breast Surgeons MammoSite clinical trial for ductal carcinoma-in-situ of the breast. Ann Surg Oncol. Jul. 2006;13(7):967-76. [pmid: 16788759].
169 Hwang ES, Samli B, Tran KN, et al. Volume of resection in patients treated with breast conservation for ductal carcinoma in situ. Ann Surg Oncol. Dec. 1998;5(8):757-63. [pmid: 9869524].
170 Ottesen GL, Graversen HP, Blichert-Toft M, et al. Ductal carcinoma in situ of the female breast. Short-term results of a prospective nationwide study. The Danish Breast Cancer Cooperative Group. Am J Surg Pathol. Dec. 1992;16(12):1183-96. [pmid: 1334379].
171 Kestin LL, Goldstein NS, Lacerna MD, et al. Factors associated with local recurrence of mammographically detected ductal carcinoma in situ in patients given breast-conserving therapy. Cancer. Feb 1. 2000;88(3):596-607. [pmid: 10649253].
172 Harris EE, Schultz DJ, Peters CA, et al. Relationship of family history and outcome after breast conservation therapy in women with ductal carcinoma in situ of the breast. Int J Radiat Oncol Biol Phys. Nov 1. 2000;48(4):933-41. [pmid: 11072148].
173 Boland GP, Chan KC, Knox WF, et al. Value of the Van Nuys Prognostic Index in prediction of recurrence of ductal carcinoma in situ after breast-conserving surgery. Br J Surg. Apr. 2003;90(4):426-32. [pmid: 12673743].
174 Vicini FA, Kestin LL, Goldstein NS, et al. Impact of young age on outcome in patients with ductal carcinoma-in-situ treated with breast-conserving therapy. J Clin Oncol. Jan. 2000;18(2):296-306. [pmid: 10637243].
175 Vicini F, Beitsch PD, Quiet CA, et al. Three-year analysis of treatment efficacy, cosmesis, and toxicity by the American Society of Breast Surgeons MammoSite Breast Brachytherapy Registry Trial in patients treated with accelerated partial breast irradiation (APBI). Cancer. Feb 15. 2008;112(4):758-66. [pmid: 18181095].
176 Dawood S, Broglio K, Gonzalez-Angulo AM, et al. Development of new cancers in patients with DCIS: the M.D. Anderson experience. Ann Surg Oncol. Jan. 2008;15(1):244-9. [pmid: 18043978].
177 Ernster VL, Barclay J, Kerlikowske K, et al. Mortality among women with ductal carcinoma in situ of the breast in the population-based surveillance, epidemiology and end results program. Arch Intern Med. Apr 10. 2000;160(7):953-8. [pmid: 10761960].
178 Schairer C, Mink PJ, Carroll L, et al. Probabilities of death from breast cancer and other causes among female breast cancer patients. J Natl Cancer Inst. Sep 1. 2004;96(17):1311-21. [pmid: 15339969].
179 Habel LA, Dignam JJ, Land SR, et al. Mammographic density and breast cancer after ductal carcinoma in situ. J Natl Cancer Inst. Oct 6. 2004;96(19):1467-72. [pmid: 15467036].
180 Vicini FA, Kestin LL, Goldstein NS, et al. Relationship between excision volume, margin status, and tumor size with the development of local recurrence in patients with ductal carcinoma-in-situ treated with breast-conserving therapy. J Surg Oncol. Apr. 2001;76(4):245-54. [pmid: 11320515].
181 Vargas C, Kestin L, Go N, et al. Factors associated with local recurrence and cause-specific survival in patients with ductal carcinoma in situ of the breast treated with breast-conserving therapy or mastectomy. Int J Radiat Oncol Biol Phys. Dec 1. 2005;63(5):1514-21. [pmid: 16005576].
182 Warneke J, Grossklaus D, Davis J, et al. Influence of local treatment on the recurrence rate of ductal carcinoma in situ. J Am Coll Surg. Jun. 1995;180(6):683-8. [pmid: 7773481].
183 Fish EB, Chapman JA, Miller NA, et al. Assessment of treatment for patients with primary ductal carcinoma in situ in the breast. Ann Surg Oncol. Dec. 1998;5(8):724-32. [pmid: 9869520].
184 Liberman L, Van Zee KJ, Dershaw DD, et al. Mammographic features of local recurrence in women who have undergone breast-conserving therapy for ductal carcinoma in situ. AJR Am J Roentgenol. Feb. 1997;168(2):489-93. [pmid: 9016233].
185 Hwang ES, Miglioretti DL, Ballard-Barbash R, et al. Association between breast density and subsequent breast cancer following treatment for ductal carcinoma in situ. Cancer Epidemiol Biomarkers Prev. Dec. 2007;16(12):2587-93. [pmid: 18086762].
186 Ringberg A, Idvall I, Ferno M, et al. Ipsilateral local recurrence in relation to therapy and morphological characteristics in patients with ductal carcinoma in situ of the breast. Eur J Surg Oncol. Aug. 2000;26(5):444-51. [pmid: 11016463].
187 Ringberg A, Anagnostaki L, Anderson H, et al. Cell biological factors in ductal carcinoma in situ (DCIS) of the breast-relationship to ipsilateral local recurrence and histopathological characteristics. Eur J Cancer. Aug. 2001;37(12):1514-22. [pmid: 11506959].
188 Cutuli B, Cohen-Solal-le Nir C, de Lafontan B, et al. Breast-conserving therapy for ductal carcinoma in situ of the breast: the French Cancer Centers’ experience. Int J Radiat Oncol Biol Phys. Jul 15. 2002;53(4):868-79. [pmid: 12095552].
189 Deutsch M, Land SR, Begovic M, et al. An association between postoperative radiotherapy for primary breast cancer in 11 National Surgical Adjuvant Breast and Bowel Project (NSABP) studies and the subsequent appearance of pleural mesothelioma. Am J Clin Oncol. Jun. 2007;30(3):294-6. [pmid: 17551308].
190 Silverstein MJ, Buchanan C. Ductal carcinoma in situ: USC/Van Nuys Prognostic Index and the impact of margin status. Breast. Dec. 2003;12(6):457-71. [pmid: 14659122].
191 MacDonald HR, Silverstein MJ, Mabry H, et al. Local control in ductal carcinoma in situ treated by excision alone: incremental benefit of larger margins. Am J Surg. Oct. 2005;190(4):521-5. [pmid: 16164913].
192 Macdonald HR, Silverstein MJ, Lee LA, et al. Margin width as the sole determinant of local recurrence after breast conservation in patients with ductal carcinoma in situ of the breast. Am J Surg. Oct. 2006;192(4):420-2. [pmid: 16978941].
193 Nakamura S, Woo C, Silberman H, et al. Breast-conserving therapy for ductal carcinoma in situ: a 20-year experience with excision plus radiation therapy. Am J Surg. Nov. 2002;184(5):403-9. [pmid: 12433602].
194 Silverstein MJ, Lagios MD, Craig PH, et al. A prognostic index for ductal carcinoma in situ of the breast. Cancer. Jun 1. 1996;77(11):2267-74. [pmid: 8635094].
195 Silverstein MJ, Poller DN, Waisman JR, et al. Prognostic classification of breast ductal carcinoma-in-situ. Lancet. May 6. 1995;345(8958):1154-7. [pmid: 7723550].
196 Silverstein MJ, Barth A, Poller DN, et al. Ten-year results comparing mastectomy to excision and radiation therapy for ductal carcinoma in situ of the breast. Eur J Cancer. 1995;31A(9):1425-7. [pmid: 7577065].
197 Silverstein MJ, Cohlan BF, Gierson ED, et al. Duct carcinoma in situ: 227 cases without microinvasion. Eur J Cancer. 1992;28(2–3):630-4. [pmid: 1317201].
198 Silverstein MJ, Waisman JR, Gierson ED, et al. Radiation therapy for intraductal carcinoma. Is it an equal alternative?. Arch Surg. Apr. 1991;126(4):424-8. [pmid: 1848972].
199 Amichetti M, Caffo O, Richetti A, et al. Ten-year results of treatment of ductal carcinoma in situ (DCIS) of the breast with conservative surgery and radiotherapy. Eur J Cancer. Sep. 1997;33(10):1559-65. [pmid: 9389915].
200 Chuwa EW, Tan VH, Tan PH, et al. Treatment for ductal carcinoma in situ in an Asian population: outcome and prognostic factors. ANZ J Surg. Jan–Feb. 2008;78:1-2. 42. 8.
201 Mirza NQ, Vlastos G, Meric F, et al. Ductal carcinoma-in-situ: long-term results of breast-conserving therapy. Ann Surg Oncol. Oct. 2000;7(9):656-64. [pmid: 11034242].
202 Chagpar A, Yen T, Sahin A, et al. Intraoperative margin assessment reduces reexcision rates in patients with ductal carcinoma in situ treated with breast-conserving surgery. Am J Surg. Oct. 2003;186(4):371-7. [pmid: 14553853].
203 Miller NA, Chapman JA, Fish EB, et al. In situ duct carcinoma of the breast: clinical and histopathologic factors and association with recurrent carcinoma. Breast J. Sep–Oct. 2001;7(5):292-302. [pmid: 11906438].
204 Adepoju LJ, Symmans WF, Babiera GV, et al. Impact of concurrent proliferative high-risk lesions on the risk of ipsilateral breast carcinoma recurrence and contralateral breast carcinoma development in patients with ductal carcinoma in situ treated with breast-conserving therapy. Cancer. Jan 1. 2006;106(1):42-50. [pmid: 16333852].
205 Takeda A, Shigematsu N, Kondo M, et al. Breast-conserving therapy for ductal carcinoma in situ. Oncol Rep. Jul–Aug. 2001;8(4):835-9. [pmid: 11410794].
206 Ben-David MA, Sturtz DE, Griffith KA, et al. Long-term results of conservative surgery and radiotherapy for ductal carcinoma in situ using lung density correction: the University of Michigan experience. Breast J. Jul–Aug. 2007;13(4):392-400. [pmid: 17593044].
207 Asjoe FT, Altintas S, Colpaert C, et al. The value of the Van Nuys Prognostic Index in ductal carcinoma in situ of the breast: a retrospective analysis. Breast J. Jul–Aug. 2007;13(4):359-67. [pmid: 17593040].
208 Kestin LL, Goldstein NS, Martinez AA, et al. Mammographically detected ductal carcinoma in situ treated with conservative surgery with or without radiation therapy: patterns of failure and 10-year results. Ann Surg. Feb. 2000;231(2):235-45. [pmid: 10674616].
209 Goldstein NS, Kestin L, Vicini F. Intraductal carcinoma of the breast: pathologic features associated with local recurrence in patients treated with breast-conserving therapy. Am J Surg Pathol. Aug. 2000;24(8):1058-67. [pmid: 10935646].
210 Lee LA, Silverstein MJ, Chung CT, et al. Breast cancer-specific mortality after invasive local recurrence in patients with ductal carcinoma-in-situ of the breast. Am J Surg. Oct. 2006;192(4):416-9. [pmid: 16978940].
211 Meijnen P, Oldenburg HS, Peterse JL, et al. Clinical outcome after selective treatment of patients diagnosed with ductal carcinoma in situ of the breast. Ann Surg Oncol. Jan. 2008;15(1):235-43. [pmid: 17987342].
212 Di Saverio S, Catena F, Santini D, et al. 259 Patients with DCIS of the breast applying USC/Van Nuys prognostic index: a retrospective review with long term follow up. Breast Cancer Res Treat. Jun. 2008;109(3):405-16. [pmid: 17687650].
213 Cataliotti L, Distante V, Ciatto S, et al. Intraductal breast cancer: review of 183 consecutive cases. Eur J Cancer. 1992;28A(4–5):917-20. [pmid: 1326310].
214 Ciatto S, Bonardi R, Cataliotti L, et al. Intraductal breast carcinoma. Review of a multicenter series of 350 cases. Coordinating Center and Writing Committee of FONCAM (National Task Force for Breast Cancer), Italy. Tumori. Dec 31. 1990;76(6):552-4. [pmid: 2178285].
215 MacAusland SG, Hepel JT, Chong FK, et al. An attempt to independently verify the utility of the Van Nuys Prognostic Index for ductal carcinoma in situ. Cancer. Dec 15. 2007;110(12):2648-53. [pmid: 17960606].
216 Sahoo S, Recant WM, Jaskowiak N, et al. Defining negative margins in DCIS patients treated with breast conservation therapy: The University of Chicago experience. Breast J. Jul–Aug. 2005;11(4):242-7. [pmid: 15982389].
217 Amichetti M, Caffo O, Richetti A, et al. Subclinical ductal carcinoma in situ of the breast: treatment with conservative surgery and radiotherapy. Tumori. Nov–Dec. 1999;85(6):488-93. [pmid: 10774571].
218 Dimpfl T, Genz T, Hecher C, et al. Intraductal carcinoma (DCIS) of the breast. Risk-adapted tumor surgery with axillary lymphadenectomy?. Eur J Gynaecol Oncol. 1996;17(2):104-9. [pmid: 8654465].
219 Vapiwala N, Harris E, Hwang WT, et al. Long-term outcome for mammographically detected ductal carcinoma in situ managed with breast conservation treatment: prognostic significance of reexcision. Cancer J. Jan–Feb. 2006;12(1):25-32. [pmid: 16613659].
220 Solin LJ, McCormick B, Recht A, et al. Mammographically detected, clinically occult ductal carcinoma in situ treated with breast-conserving surgery and definitive breast irradiation. Cancer J Sci Am. May–Jun. 1996;2(3):158-65. [pmid: 9166516].
221 Solin LJ, Kurtz J, Fourquet A, et al. Fifteen-year results of breast-conserving surgery and definitive breast irradiation for the treatment of ductal carcinoma in situ of the breast. J Clin Oncol. Mar. 1996;14(3):754-63. [pmid: 8622021].
222 Solin LJ, Yeh IT, Kurtz J, et al. Ductal carcinoma in situ (intraductal carcinoma) of the breast treated with breast-conserving surgery and definitive irradiation. Correlation of pathologic parameters with outcome of treatment. Cancer. Apr 15. 1993;71(8):2532-42. [pmid: 8384070].
223 Stallard S, Hole DA, Purushotham AD, et al. Ductal carcinoma in situ of the breast -- among factors predicting for recurrence, distance from the nipple is important. Eur J Surg Oncol. Jun. 2001;27(4):373-7. [pmid: 11417983].
224 Szelei-Stevens KA, Kuske RR, Yantsos VA, et al. The influence of young age and positive family history of breast cancer on the prognosis of ductal carcinoma in situ treated by excision with or without radiation therapy or by mastectomy. Int J Radiat Oncol Biol Phys. Nov 1. 2000;48(4):943-9. [pmid: 11072149].
225 Van Zee KJ, Liberman L, Samli B, et al. Long term follow-up of women with ductal carcinoma in situ treated with breast-conserving surgery: the effect of age. Cancer. Nov 1. 1999;86(9):1757-67. [pmid: 10547549].
226 Warnberg F, Bergh J, Zack M, et al. Risk factors for subsequent invasive breast cancer and breast cancer death after ductal carcinoma in situ: a population-based case-control study in Sweden. Cancer Epidemiol Biomarkers Prev. May. 2001;10(5):495-9. [pmid: 11352860].
227 Warnberg F, Casalini P, Nordgren H, et al. Ductal carcinoma in situ of the breast: a new phenotype classification system and its relation to prognosis. Breast Cancer Res Treat. Jun. 2002;73(3):215-21. [pmid: 12160327].
228 Warnberg F, Nordgren H, Bergh J, et al. Ductal carcinoma in situ of the breast from a population-defined cohort: an evaluation of new histopathological classification systems. Eur J Cancer. May. 1999;35(5):714-20. [pmid: 10505030].
229 Holland PA, Gandhi A, Knox WF, et al. The importance of complete excision in the prevention of local recurrence of ductal carcinoma in situ. Br J Cancer. 1998;77(1):110-4. [pmid: 9459154].
230 Fowble B, Hanlon AL, Fein DA, et al. Results of conservative surgery and radiation for mammographically detected ductal carcinoma in situ (DCIS). Int J Radiat Oncol Biol Phys. Jul 15. 1997;38(5):949-57. [pmid: 9276359].
231 Lara JF, Young SM, Velilla RE, et al. The relevance of occult axillary micrometastasis in ductal carcinoma in situ: a clinicopathologic study with long-term follow-up. Cancer. Nov 15. 2003;98(10):2105-13. [pmid: 14601079].
232 Idvall I, Anderson H, Ringberg A, et al. Are cellular polarisation and mitotic frequency prognostic factors for local recurrence in patients with ductal carcinoma in situ of the breast?. Eur J Cancer. Aug. 2003;39(12):1704-10. [pmid: 12888365].
233 Rodriguez N, Sanz X, Algara M, et al. Conservative treatment in noninvasive breast cancer. Tumori. Jan–Feb. 2004;90(1):17-21. [pmid: 15143965].
234 Benitez PR, Streeter O, Vicini F, et al. Preliminary results and evaluation of MammoSite balloon brachytherapy for partial breast irradiation for pure ductal carcinoma in situ: a phase II clinical study. Am J Surg. Oct. 2006;192(4):427-33. [pmid: 16978943].
235 Douglas-Jones AG, Logan J, Morgan JM, et al. Effect of margins of excision on recurrence after local excision of ductal carcinoma in situ of the breast. J Clin Pathol. Aug. 2002;55(8):581-6. [pmid: 12147650].
236 Gilleard O, Goodman A, Cooper M, et al. The significance of the Van Nuys prognostic index in the management of ductal carcinoma in situ. World Journal of Surgical Oncology. 2008;6:61. [pmid: 18564426].
237 Omlin A, Amichetti M, Azria D, et al. Boost radiotherapy in young women with ductal carcinoma in situ: a multicentre, retrospective study of the Rare Cancer Network. Lancet Oncol. Aug. 2006;7(8):652-6. [pmid: 16887482].
238 Habel LA, Daling JR, Newcomb PA, et al. Risk of recurrence after ductal carcinoma in situ of the breast. Cancer Epidemiol Biomarkers Prev. Aug. 1998;7(8):689-96. [pmid: 9718221].
239 Ellsworth RE, Ellsworth DL, Love B, et al. Correlation of levels and patterns of genomic instability with histological grading of DCIS. Ann Surg Oncol. Nov. 2007;14(11):3070-7. [pmid: 17549568].
240 Ottesen GL, Graversen HP, Blichert-Toft M, et al. Carcinoma in situ of the female breast. 10 year follow-up results of a prospective nationwide study. Breast Cancer Res Treat. Aug. 2000;62(3):197-210. [pmid: 11072784].
241 Kollias J, Ellis IO, Elston CW, et al. Clinical and histological predictors of contralateral breast cancer. Eur J Surg Oncol. Dec. 1999;25(6):584-9. [pmid: 10556004].
242 Jha MK, Avlonitis VS, Griffith CD, et al. Aggressive local treatment for screen-detected DCIS results in very low rates of recurrence. Eur J Surg Oncol. Aug. 2001;27(5):454-8. [pmid: 11504515].
243 Rakovitch E, Pignol JP, Hanna W, et al. Significance of multifocality in ductal carcinoma in situ: outcomes of women treated with breast-conserving therapy. J Clin Oncol. Dec 10. 2007;25(35):5591-6. [pmid: 17984188].
244 Pinsky RW, Rebner M, Pierce LJ, et al. Recurrent cancer after breast-conserving surgery with radiation therapy for ductal carcinoma in situ: mammographic features, method of detection, and stage of recurrence. AJR Am J Roentgenol. Jul. 2007;189(1):140-4. [pmid: 17579163].
245 Carlson GW, Page A, Johnson E, et al. Local recurrence of ductal carcinoma in situ after skin-sparing mastectomy. J Am Coll Surg. May. 2007;204(5:):1074-8. discussion 8–80. [pmid: 17481544].
246 Kricker A, Armstrong B. Surgery and outcomes of ductal carcinoma in situ of the breast: a population-based study in Australia. Eur J Cancer. Nov. 2004;40(16):2396-402. [pmid: 15519511].
247 Temple WJ, Jenkins M, Alexander F, et al. Natural history of in situ breast cancer in a defined population. Ann Surg. Nov. 1989;210(5):653-7. [pmid: 2554827].
248 Franceschi S, Levi F, La Vecchia C, et al. Second cancers following in situ carcinoma of the breast. Int J Cancer. 07. 29. 1998;77(3):392-5. [pmid: 9663601].
249 Li CI, Malone KE, Saltzman BS, et al. Risk of invasive breast carcinoma among women diagnosed with ductal carcinoma in situ and lobular carcinoma in situ, 1988–2001. Cancer. May 15. 2006;106(10):2104-12. [pmid: 16604564].
250 Schouten van der Velden AP, Peeters PH, Koot VC, et al. Local recurrences after conservative treatment of ductal carcinoma-in-situ of the breast without radiotherapy: the effect of age. Ann Surg Oncol. Jul. 2006;13(7):990-8. [pmid: 16788762].
251 Jhingran A, Kim JS, Buchholz TA, et al. Age as a predictor of outcome for women with DCIS treated with breast-conserving surgery and radiation: The University of Texas M. D. Anderson Cancer Center experience. Int J Radiat Oncol Biol Phys. Nov 1. 2002;54(3):804-9. [pmid: 12377332].
252 Habel LA, Moe RE, Daling JR, et al. Risk of contralateral breast cancer among women with carcinoma in situ of the breast. Ann Surg. Jan. 1997;225(1):69-75. [pmid: 8998122].
253 Tan PH, Chuah KL, Chiang G, et al. Correlation of p53 and cerbB2 expression and hormonal receptor status with clinicopathologic parameters in ductal carcinoma in situ of the breast. Oncol Rep. Sep–Oct. 2002;9(5):1081-6. [pmid: 12168077].
254 Roka S, Rudas M, Taucher S, et al. High nuclear grade and negative estrogen receptor are significant risk factors for recurrence in DCIS. Eur J Surg Oncol. Apr. 2004;30(3):243-7. [pmid: 15028303].
255 Wilson GR, Cramer A, Welman A, et al. Activated c-SRC in ductal carcinoma in situ correlates with high tumour grade, high proliferation and HER2 positivity. Br J Cancer. Nov 20. 2006;95(10):1410-4. [pmid: 17060931].
256 Warnberg F, Amini RM, Goldman M, et al. Quality aspects of the tissue microarray technique in a population-based cohort with ductal carcinoma in situ of the breast. Histopathology. Dec. 2008;53(6):642-9. [pmid: 19076680].
257 Rudloff U, Brogi E, Brockway JP, et al. Concurrent lobular neoplasia increases the risk of ipsilateral breast cancer recurrence in patients with ductal carcinoma in situ treated with breast-conserving therapy. Cancer. 2009. Jan 23.
258 Trisal V, Qian D, Wagman LD. Axillary recurrence in DCIs: is axillary lymphadenectomy warranted?. Am Surg. Oct. 2004;70(10):876-80. [pmid: 15529841].
259 Innos K, Horn-Ross PL. Risk of second primary breast cancers among women with ductal carcinoma in situ of the breast. Breast Cancer Research & Treatment. Oct. 2008;111(3):531-40. [pmid: 17978879].
260 West JG, Qureshi A, Liao SY, et al. Multidisciplinary management of ductal carcinoma in situ: a 10-year experience. Am J Surg. Oct. 2007;194(4):532-4. [pmid: 17826074].
261 de Roos MA, de Bock GH, Baas PC, et al. Compliance with guidelines is related to better local recurrence-free survival in ductal carcinoma in situ. Br J Cancer. Nov 14. 2005;93(10):1122-7. [pmid: 16234825].
262 Cox CE, Hyacinthe M, Gonzalez RJ, et al. Cytologic evaluation of lumpectomy margins in patients with ductal carcinoma in situ: clinical outcome. Ann Surg Oncol. Dec. 1997;4(8):644-9. [pmid: 9416412].
263 Ciatto S, Grazzini G, Iossa A, et al. In situ ductal carcinoma of the breast--analysis of clinical presentation and outcome in 156 consecutive cases. Eur J Surg Oncol. Jun. 1990;16(3):220-4. [pmid: 2161353].
264 Page DL, Dupont WD, Rogers LW, et al. Continued local recurrence of carcinoma 15–25 years after a diagnosis of low grade ductal carcinoma in situ of the breast treated only by biopsy. Cancer. Oct 1. 1995;76(7):1197-200. [pmid: 8630897].
265 Sanders ME, Schuyler PA, Dupont WD, et al. The natural history of low-grade ductal carcinoma in situ of the breast in women treated by biopsy only revealed over 30 years of long-term follow-up. Cancer. Jun 15. 2005;103(12):2481-4. [pmid: 15884091].
266 Metz JM, Solin LJ. Long-term outcome after postmastectomy radiation therapy for the treatment of ductal carcinoma in situ of the breast. Am J Clin Oncol. Jun. 1999;22(3):215-7. [pmid: 10362324].
267 de Mascarel I, MacGrogan G, Mathoulin-Pelissier S, et al. Breast ductal carcinoma in situ with microinvasion: a definition supported by a long-term study of 1248 serially sectioned ductal carcinomas. Cancer. Apr 15. 2002;94(8):2134-42. [pmid: 12001109].
268 Kepple J, Henry-Tillman RS, Klimberg VS, et al. The receptor expression pattern in ductal carcinoma in situ predicts recurrence. Am J Surg. Jul. 2006;192(1):68-71. [pmid: 16769278].
269 Bowers GJ, Roettger RH, McAuley CE, et al. Breast cancer: the military’s experience at Wilford Hall USAF Medical Center. South Med J. Dec. 1990;83(12):1413-7. [pmid: 2174576].
270 de Roos MA, de Bock GH, de Vries J, et al. p53 overexpression is a predictor of local recurrence after treatment for both in situ and invasive ductal carcinoma of the breast. J Surg Res. Jun 1. 2007;140(1):109-14. [pmid: 17291532].
271 Jiveliouk I, Corn B, Inbar M, et al. Ductal carcinoma in situ of the breast in Israeli women treated by breast-conserving surgery followed by radiation therapy. Oncology. 2009;76(1):30-5. [pmid: 19033713].
272 Badve S, A’Hern RP, Ward AM, et al. Prediction of local recurrence of ductal carcinoma in situ of the breast using five histological classifications: a comparative study with long follow-up. Hum Pathol. Sep. 1998;29(9):915-23. [pmid: 9744307].
273 Provenzano E, Hopper JL, Giles GG, et al. Biological markers that predict clinical recurrence in ductal carcinoma in situ of the breast. Eur J Cancer. Mar. 2003;39(5):622-30. [pmid: 12628841].
274 Barnes NL, Khavari S, Boland GP, et al. Absence of HER4 expression predicts recurrence of ductal carcinoma in situ of the breast. Clin Cancer Res. Mar 15. 2005;11(6):2163-8. [pmid: 15788662].
275 Amichetti M, Caffo O, Arcicasa M, et al. Quality of life in patients with ductal carcinoma in situ of the breast treated with conservative surgery and postoperative irradiation. Breast Cancer Res Treat. Mar. 1999;54(2):109-15. [pmid: 10424401].
276 Turaka A, Freedman GM, Li T, et al. Young age is not associated with increased local recurrence for DCIS treated by breast-conserving surgery and radiation. J Surg Oncol. 2009. Apr 16.
277 Kinne DW, Petrek JA, Osborne MP, et al. Breast carcinoma in situ. Arch Surg. Jan. 1989;124(1):33-6. [pmid: 2535929].
278 Ward BA, McKhann CF, Ravikumar TS. Ten-year follow-up of breast carcinoma in situ in Connecticut. Arch Surg. Dec. 1992;127(12):1392-5. [pmid: 1365682].
279 Rosner D, Bedwani RN, Vana J, et al. Noninvasive breast carcinoma: results of a national survey by the American College of Surgeons. Ann Surg. Aug. 1980;192(2):139-47. [pmid: 6250497].
280 Silverstein MJ. Ductal carcinoma in situ of the breast: 11 reasons to consider treatment with excision alone. Womens Health (Lond Engl). Nov. 2008;4(6):565-77. [pmid: 19072459].
281 Bellamy CO, McDonald C, Salter DM, et al. Noninvasive ductal carcinoma of the breast: the relevance of histologic categorization. Hum Pathol. Jan. 1993;24(1):16-23. [pmid: 8380275].
282 Bijker N, Meijnen P, Peterse JL, et al. Breast-conserving treatment with or without radiotherapy in ductal carcinoma-in-situ: ten-year results of European Organisation for Research and Treatment of Cancer randomized phase III trial 10853--a study by the EORTC Breast Cancer Cooperative Group and EORTC Radiotherapy Group. J Clin Oncol. Jul 20. 2006;24(21):3381-7. [pmid: 16801628].
283 Fisher ER, Dignam J, Tan-Chiu E, et al. Pathologic findings from the National Surgical Adjuvant Breast Project (NSABP) eight-year update of Protocol B-17: intraductal carcinoma. Cancer. Aug 1. 1999;86(3):429-38. [pmid: 10430251].
284 Fisher B, Land S, Mamounas E, et al. Prevention of invasive breast cancer in women with ductal carcinoma in situ: an update of the national surgical adjuvant breast and bowel project experience. Semin Oncol. Aug. 2001;28(4):400-18. [pmid: 11498833].