# Abstraction Forms

## What are the incidence and prevalence of DCIS and its specific pathologic subtypes, and how are incidence and prevalence influenced by mode of detection, population characteristics?

## What are the incidence and prevalence of DCIS and its specific pathologic subtypes by risk factors?

## How does the use of MRI or sentinel lymph node biopsy impact important outcomes in patients diagnosed with DCIS?

- Mastectomy rates
- In-breast recurrence of DCIS or invasive cancer
- Rates of metastases
- Disease-specific survival rates
- Rates of chemotherapy or hormonal therapy use

## How do local control and systemic outcomes vary in DCIS based on tumor and patient characteristics?

- In patients with DCIS, what is the impact of surgery, radiation, and systemic treatment on outcomes?

## How do local control and systemic outcomes vary in DCIS based on tumor and patient characteristics?

- In patients with DCIS, what is the impact of surgery, radiation, and systemic treatment on outcomes