# Analytical Framework

Appendix D contains details on analytical framework of the report: algorithm to define eligibility of the studies, definitions, hypotheses, and statistical models.

## Identifying Studies Eligible for Research Questions

1. What are the incidence and prevalence of DCIS and its specific pathologic subtypes, and how are incidence and prevalence influenced by population characteristics?
  - Age
  - Race

## Verification/Selection of Study Eligibility

Criteria 1 - Confirm eligibility of the target population

Eligible descriptors:

Adult females in the community | Yes | No
If NO – exclude

Criteria 2 - Confirm eligibility of the outcomes

Eligible descriptors:

Prevalence of ductal carcinoma* in situ | Yes | No
Incidence of ductal carcinoma* in situ | Yes | No

* Possible synonyms of ductal carcinoma in situ: noninfiltrating intraductal carcinoma, carcinoma in situ, intraductal carcinoma, ductal carcinoma in situ of the breast, localized breast cancer.

If No – exclude

Criteria 3. Confirm eligible level of evidence

Eligible descriptors:

Large population-based cross sectional analyses | Yes | No
Large population-based cohort studies | Yes | No
If NO for all descriptors – exclude

This evaluation can be possible after reviewing the full text of the articles

1A. How are incidence and prevalence influenced by mode of detection, genetics, menopausal hormone therapy use, body mass index, mammographic breast density, and other risk factors?

Criteria 1 - Confirm eligibility of the target population

Eligible descriptors:

Adult females in the community | Yes | No
If NO – exclude

Criteria 2 - Confirm eligibility of the outcomes

Eligible descriptors:

Prevalence of ductal carcinoma* in situ | Yes | No
Incidence of ductal carcinoma* in situ | Yes | No

Possible* synonyms of ductal carcinoma in situ: noninfiltrating intraductal carcinoma, carcinoma in situ, intraductal carcinoma, ductal carcinoma in situ of the breast, localized breast cancer;

If No – exclude

Criteria 3. Confirm eligible level of evidence- the studies that examined the association between incident or prevalent ductal breast carcinoma in situ with risk factors AND obtained at least one strategy to reduce bias including multivariate analysis, matching, stratification, or propensity scores.

This evaluation can be possible after reviewing the full text of the articles

Eligible descriptors:

Large population-based cross sectional analysis | Yes | No
Large population-based cohort studies | Yes | No
Clinical trials | Yes | No
Analysis of Medicare database | Yes | No
Analysis of cancer registries | Yes | No
Case-control study | Yes | No
If NO for all descriptors – exclude

2. How does the use of MRI or sentinel lymph node biopsy impact important outcomes in patients diagnosed with DCIS?

- Mastectomy rates
- In-breast recurrence of DCIS or invasive cancer
- Rates of metastases
- Disease-specific survival rates
- Rates of chemotherapy or hormonal therapy use

## Verification/Selection of Study Eligibility

Criteria 1 – Confirm eligibility of the target population

Eligible descriptors:

Adult females with DCIS | Yes | No
If NO – exclude

Criteria 2 – Confirm eligibility of the outcomes

Eligible descriptors:

• Mastectomy rates | Yes | No
• In-breast recurrence of DCIS or invasive cancer | Yes | No
• Rates of metastases | Yes | No
• Disease-specific survival rates | Yes | No
• Rates of chemotherapy or hormonal therapy use | Yes | No

If No for all descriptors – exclude

Criteria 3 – Confirm eligibility of diagnostic strategies

Eligible descriptors:

• Self exam | Yes | No
• Clinical exam | Yes | No
• Active screening | Yes | No
• Mammography | Yes | No
• Ultrasound | Yes | No
• MRI | Yes | No
• Sentinel lymph node biopsy | Yes | No

If NO for all descriptors – exclude

Criteria 4 - Confirm eligible level of evidence: the studies that examined probability of the outcomes in association to detection of DCIS with MRI or node biopsy AND obtained at least one strategy to reduce bias including multivariate analysis, matching, stratification, or propensity scores

This evaluation can be possible after reviewing the full text of the articles.

3. How do local control and systemic outcomes vary in DCIS based on tumor and patient characteristics?

- Tumor/Patient Characteristics:
- Specimen radiography features
  - Margin status (width)
  - Tumor size
  - Histological grade
  - ER/PR status
  - Volume of tumor evaluated

## Verification/Selection of Study Eligibility

Criteria 1 - Confirm eligibility of the target population

Eligible descriptors:

Adult females with DCIS | Yes | No
If NO – exclude

Criteria 2 – Confirm eligibility of the outcomes

Eligible descriptors:

• In-breast recurrence of DCIS or invasive cancer | Yes | No
• Contralateral disease | Yes | No
• Rates of metastases | Yes | No
• Disease-specific survival rates | Yes | No

If No for all descriptors – exclude

Criteria 3- Confirm eligibility of independent variable:

Eligible descriptors:

- Specimen radiography features
- Margin status (width)
- Tumor size
- Histological grade
- ER/PR status
- Volume of tumor evaluated

If No for all descriptors– exclude

Criteria 4 - Confirm eligible level of evidence: The studies that examined probability of the outcomes in association to tumor characteristics AND obtained at least one strategy to reduce bias including multivariate analysis, matching, stratification, or propensity score.

This evaluation can be possible after reviewing the full text of the articles

3. In patients with DCIS, what is the impact of surgery, radiation, and systemic treatment on outcomes?

- Systemic treatment = tamoxifen and raloxifene
- Outcomes:
  - Local, regional, and distant recurrence
  - Contralateral disease
  - Disease-specific survival

## Verification/Selection of Study Eligibility

Criteria 1 – Confirm eligibility of the target population

Eligible descriptors:

Adult females with DCIS | Yes | No
If NO – exclude

Criteria 2 - Confirm eligibility of interventions

Eligible descriptors:

•Surgery | Yes | No
•Radiation | Yes | No
•Tamoxifen | Yes | No
•Raloxifene | Yes | No

Control intervention- Placebo, no active treatment, other active treatment

If No for all descriptors - exclude

Criteria 3 – Confirm eligibility of outcomes.

Eligible descriptors:

•Local, regional, and distant recurrence | Yes | No
•Contralateral disease | Yes | No
•Disease-specific survival | Yes | No

If No for all descriptors – exclude

Criteria 4 - Confirm eligible level of evidence: The studies that examined probability of the outcomes after different treatment options AND obtained at least one strategy to reduce bias including multivariate analysis, matching, stratification, or propensity scores.

This evaluation can be possible after reviewing the full text of the articles

* Possible synonyms of ductal carcinoma in situ: noninfiltrating intraductal carcinoma, carcinoma in situ, intraductal carcinoma, ductal carcinoma in situ of the breast, localized breast cancer.

## Operational definitions

Carcinoma, Intraductal, Noninfiltrating (Ductal carcinoma in situ)1 - A noninvasive (noninfiltrating) carcinoma of the breast characterized by a proliferation of malignant epithelial cells confined to the mammary ducts or lobules, without light-microscopy evidence of invasion through the basement membrane into the surrounding stroma.

Adenocarcinoma, Scirrhous1 - An adenocarcinoma with a hard (Greek skirrhos, hard) structure owing to the formation of dense connective tissue in the stroma. (From Dorland, 27th ed)

Adenocarcinoma1 - A malignant epithelial tumor with a glandular organization.

Carcinoma in Situ1 - A lesion with cytological characteristics associated with invasive carcinoma but the tumor cells are confined to the epithelium of origin, without invasion of the basement membrane.

Carcinoma, Adenoid Cystic1 - Carcinoma characterized by bands or cylinders of hyalinized or mucinous stroma separating or surrounded by nests or cords of small epithelial cells. When the cylinders occur within masses of epithelial cells, they give the tissue a perforated, sievelike, or cribriform appearance. Such tumors occur in the mammary glands, the mucous glands of the upper and lower respiratory tract, and the salivary glands. They are malignant but slow-growing and tend to spread locally via the nerves.

Carcinoma, Ductal, Breast1 - An invasive (infiltrating) carcinoma of the mammary ductal system.

Carcinoma, Lobular1 - A infiltrating (invasive) breast cancer.

Carcinoma, Medullary1 - A carcinoma composed mainly of epithelial elements with little or no stroma. Medullary carcinomas of the breast constitute 5%–7% of all mammary carcinomas.

Carcinoma, Papillary1 - A malignant neoplasm characterized by the formation of numerous, irregular, finger-like projections of fibrous stroma that is covered with a surface layer of neoplastic epithelial cells.

Sentinel node biopsy1 - A diagnostic procedure used to determine whether lymphatic metastasis has occurred; removal and examination of the sentinel node(s) (the first lymph node(s) to which cancer cells are likely to spread from a primary tumor). The sentinel lymph node is the first lymph node to receive drainage from a neoplasm

We used the USC/Van Nuys Prognostic Index scoring system for tumor characteristics2 when one to three points are awarded for each of four different predictors of local breast recurrence (size, margin width, pathologic classification, and age). Scores for each of the predictors are totaled to yield a VNPI score ranging from a low of 4 to a high of 12.

Score | 1 | 2 | 3
Size (mm) | <15 | 16–40 | >41
Margin width (mm) | >10 | 1–9 | <1
Pathologic classification | Non high grade without necrosis | Non high grade with necrosis | High grade with or without
| (Nuclear grades 1 or 2) | (Nuclear grades 1 or 2) | Necrosis (nuclear grade 3)
Age (years) | >60 | 40–60 | <40

We used the following definitions for different forms of DCIS http://www.accessmedicine.com :

Multicentricity. Multicentricity is defined as DCIS in a quadrant other than the index quadrant

Multifocality. Multifocality is generally considered to be present when separate foci of DCIS occur more than 5 mm apart in the same breast quadrant.

Microinvasion. Predominantly noninvasive lesion with foci of invasive cancer, each measuring less than 1 mm. Larger areas of invasive growth are termed “minimally invasive carcinoma” (T1a=1–5 mm and T1b=5–10 mm)

We applied proposed standardized definitions for breast cancer clinical trial end points in the adjuvant setting.3

End Point | Invasive Ipsilateral Breast Tumor Recurrence | Local/Regional Invasive Recurrence | Distant Recurrence | Death From Breast Cancer | Death From Nonbreast Cancer Cause | Death From Unknown Cause | Invasive Contralateral Breast Cancer | Ipsilateral DCIS | Contralateral DCIS | Second Primary Invasive Cancer (nonbreast)
Overall survival | | | | X | X | X
Disease-free survival-ductal carcinoma in situ | X | X | X | X | X | X | X | X | X | X
Invasive disease- free survival-invasive | X | X | X | X | X | X | X | | | X
Distant disease-free survival | | | X | X | X | X | | | | X
Distant relapse-free survival | | | X | X | X | X
Recurrence-free survival | X | X | X | X | X | X
Recurrence-free interval | X | X | X | X
Breast cancer-free interval | X | X | X | X | | | X | X | X
Distant recurrence- free interval | | | X | X

## Study design

Definitions4

Experimental interventional studies: Investigators assign exposure.

Randomized – Exposure assigned randomly;

Not randomized - Investigators actively manipulate which groups receive intervention under the study.

Controlled experiment – Outcome levels are compared among exposed and not exposed.

Not controlled experiment – Outcomes levels are compared before and after exposure (intervention).

Observational – Investigators passively observe as nature takes its course analyzing outcomes among exposed and not exposed.

Cohort study – Subjects are defined and samples by exposure status and followed for outcomes occurrence.

Prospective cohort study - Subjects are sampled by exposure status and prospectively followed to outcome occurrence.

Retrospective cohort - Subjects are sampled at time when exposure and outcome occurred and followed retrospectively during the time to analyze outcomes levels in exposed and not exposed.

Ambidirectional cohort study – Subjects are followed in both directions, prospectively and retrospectively.

Case-control study – Subjects are defined and sampled by outcome status, the history of exposure is compared in cases and controls.

Cross-sectional – Examined relationship between exposure and outcome prevalence in a defined population at the single time point.

Ecological – Examined relationship between exposure and disease with population level rather than individual level data. Correlations in population level do not presume associations in individual levels.

Case-series - Observations on a series of cases with descriptions of outcomes levels after exposure (no control) or comparisons before and after exposure. Investigators did not assign exposure.5

Chance observations – Uncontrolled observations of outcomes levels, individual experience, low level of evidence, but must be reviewed because may lead to important discoveries (discovery of digitalis, penicillin).

[underlined: Definitions from the National Library of Medicine and the National Institute of Health:]

Epidemiologic Studies. Studies designed to examine associations, commonly, hypothesized causal relations. They are usually concerned with identifying or measuring the effects of risk factors or exposures. The common types of analytic study are CASE-CONTROL STUDIES; COHORT STUDIES; and CROSS-SECTIONAL STUDIES.

Cohort Studies. Studies in which subsets of a defined population are identified. These groups may or may not be exposed to factors hypothesized to influence the probability of the occurrence of a particular disease or other outcome. Cohorts are defined populations which, as a whole, are followed in an attempt to determine distinguishing subgroup characteristics.

Retrospective Studies. Studies used to test etiologic hypotheses in which inferences about an exposure to putative causal factors are derived from data relating to characteristics of persons under study or to events or experiences in their past. The essential feature is that some of the persons under study have the disease or outcome of interest and their characteristics are compared with those of unaffected persons.

Longitudinal Studies. Studies in which variables relating to an individual or group of individuals are assessed over a period of time.

Prospective Studies. Observation of a population for a sufficient number of persons over a sufficient number of years to generate incidence or mortality rates subsequent to the selection of the study group.

Cross-Sectional Studies. Studies in which the presence or absence of disease or other health-related variables are determined in each member of the study population or in a representative sample at one particular time. This contrasts with LONGITUDINAL STUDIES which are followed over a period of time

Case-Control Studies. Studies which start with the identification of persons with a disease of interest and a control (comparison, referent) group without the disease. The relationship of an attribute to the disease is examined by comparing diseased and nondiseased persons with regard to the frequency or levels of the attribute in each group.

Intervention Studies. Epidemiologic investigations designed to test a hypothesized cause-effect relation by modifying the supposed causal factor(s) in the study population.

Clinical Trials. Work that is the report of a pre-planned clinical study of the safety, efficacy, or optimum dosage schedule of one or more diagnostic, therapeutic, or prophylactic drugs, devices, or techniques in humans selected according to predetermined criteria of eligibility and observed for predefined evidence of favorable and unfavorable effects. While most clinical trials concern humans, this publication type may be used for clinical veterinary articles meeting the requisites for humans. Specific headings for specific types and phases of clinical trials are also available.

Clinical Trials Phase I. Studies performed to evaluate the safety of diagnostic, therapeutic, or prophylactic drugs, devices, or techniques in healthy subjects and to determine the safe dosage range (if appropriate). These tests also are used to determine pharmacologic and pharmacokinetic properties (toxicity, metabolism, absorption, elimination, and preferred route of administration). They involve a small number of persons and usually last about 1 year. This concept includes phase I studies conducted both in the U.S. and in other countries.

Clinical Trials Phase II. Studies that are usually controlled to assess the effectiveness and dosage (if appropriate) of diagnostic, therapeutic, or prophylactic drugs, devices, or techniques. These studies are performed on several hundred volunteers, including a limited number of patients with the target disease or disorder, and last about two years. This concept includes phase II studies conducted in both the U.S. and in other countries.

Clinical Trials Phase III. Comparative studies to verify the effectiveness of diagnostic, therapeutic, or prophylactic drugs, devices, or techniques determined in phase II studies. During these trials, patients are monitored closely by physicians to identify any adverse reactions from long-term use. These studies are performed on groups of patients large enough to identify clinically significant responses and usually last about three years. This concept includes phase III studies conducted in both the U.S. and in other countries.

Clinical Trials Phase IV. Planned post-marketing studies of diagnostic, therapeutic, or prophylactic drugs, devices, or techniques that have been approved for general sale. These studies are often conducted to obtain additional data about the safety and efficacy of a product. This concept includes phase IV studies conducted in both the U.S. and in other countries.

Cross-Over Studies. Studies comparing two or more treatments or interventions in which the subjects or patients, upon completion of the course of one treatment, are switched to another. In the case of two treatments, A and B, half the subjects are randomly allocated to receive these in the order A, B and half to receive them in the order B, A. A criticism of this design is that effects of the first treatment may carry over into the period when the second is given. (Last, A Dictionary of Epidemiology, 2d ed).

Case-report. Clinical presentations that may be followed by evaluative studies that eventually lead to a diagnosis

[underlined: Calculations of event rates from the original studies.] We calculated event rates with the software Meta-analyst (https://research.tufts-nemc.org/metaanalyst/metaanalyst_methods.html). Continuity corrections for 0 cells: Denote the cells of binary data in the presentation of formulae using the following variable names:

Study i | Event | No Event
Treatment | a _i_ | b _i_
Control | c _i_ | d _i_

Currently, if any of the four cells (a through d) is zero, MetaAnalyst adds 0.5 to all cells the contingency table if any of the cell expectations would cause a division by zero error. This is otherwise called the Woolf-Haldane correction (for the odds ratio).6 Binary, 1 group:

| Event | No Event
Study i | a _i_ | b _i_

We added 0.5 when one of the two cells is 0 (proportion is 0% or 100%), so that the logit transformation results quantities that can be defined.

Note: Currently, the output of MetaAnalysts lists proportions per study [underlined: using the continuity correction]. So for a study that has 0/100 events, the proportion listed in the output is 0.005 rather than 0.000.

[underlined: Algorithms of meta-analysis] 7

Pooled estimate as a weighted average:

θ_I V_ = (∑_i_ w_i_ θ_i_)/(∑_i_ w_i_)

Weights are inverse of variance (standard error):

w_i_ = (1)/(S E ( θ_i_ )^2^)

Standard error of pooled estimate:

S E ( θ_I V_ ) = (1)/(sqrt(∑_i_ w_i_))

Heterogeneity (between-study variability) measured by:

Q = ∑_i_ w_i_ ( θ_i_ - θ_I V_ )^2^

Assumptions for random effects model: true effect sizes qi have a normal distribution with mean q and variance t2; t2 is the between-study variance

Between study variance:

τ^2^ = (Q - ( k - 1 ))/(∑_i_ w_i_ - ( (∑_i_ w_i_^2^)/(∑_i_ w_i_) ))

Where:

wi are the weights from the fixed effect inverse-variance method

Q is the heterogeneity test statistic from before (either from inverse-variance method or Mantel-Haenszel method)

k is the number of studies, and

t2 is set to zero if Q<k-1

Random effect pooled estimate is weighted average:

θ_D L_ = (∑_i_ w^′^_i_ θ_i_)/(∑_i_ w^′^_i_)

Weights used for the pooled estimate are similar to the inverse-variance, but now incorporate a component for between-study variation:

w^′^_i_ = (1)/(S E ( θ_i_ )^2^ + τ^2^)

Standard error of pooled estimate

S E ( θ_D L_ ) = (1)/(sqrt(∑_i_ w^′^_i_))

Number needed to treat to prevent one event of the outcome was calculated as reciprocal to absolute risk differences in rates of outcomes events in the active and control groups:8,9 1/(control group event rate - treatment group event rate).

The number of avoided or excess events (respectively) per 1000 population is the difference between the two event rates multiplied by 1000:

(control group event rate - treatment group event rate)*1000

## References for Analytical Framework

1 National Library of Medicine (US), National Institutes of Health (U.S.). PubMed Central. PubMed Central [digital]. Bethesda, MD. National Library of Medicine. 2000.
2 Silverstein MJ. The University of Southern California/Van Nuys prognostic index for ductal carcinoma in situ of the breast. Am J Surg. Oct. 2003;186(4):337-43. [pmid: 14553846].
3 Hudis CA, Barlow WE, Costantino JP, et al. Proposal for standardized definitions for efficacy end points in adjuvant breast cancer trials: the STEEP system. J Clin Oncol. May 20. 2007;25(15):2127-32. [pmid: 17513820].
4 Aschengrau A, Seage GR. Essentials of Epidemiology in Public Health. Sudbury, Mass. Jones and Bartlett. 2003.
5 Fletcher RH, Fletcher SW, Wagner EH. Clinical Epidemiology: The Essentials. 3rd ed. Williams & Wilkins. 1996.
6 Schlesselman J, Stolley P. Case-control studies Design, conduct, analysis. New York. Oxford University Press. 1982.
7 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
8 Egger M, Smith GD, Altman DG. Systematic Reviews in Health Care. London. NetLibrary, Inc BMJ Books. 2001.
9 Ebrahim S. The use of numbers needed to treat derived from systematic reviews and meta-analysis. Caveats and pitfalls. Eval Health Prof. Jun. 2001;24(2):152-64. [pmid: 11523384].